# Discussion

## Overview

In this report, as in all efforts to systematically review and analyze a vast body of scientific evidence relating to a complex topic, it was necessary to make a number of decisions in an effort to clearly define, and in some cases, narrow the scope of this evidence review. Consequently, this review has a number of limitations. These limitations relate to the definition of violence used and, as a result, behaviors that were excluded from the review; the limitations also include the age range used to define adolescents, the timeframe of the literature reviewed, and because of the heterogeneous nature of the studies identified, the types of analysis and the kinds of conclusions we were able to draw.

First, the research staff decided to use the Centers for Disease Control and Prevention's (CDC's) definition of violence, which defines violence as “the threatened or actual physical force or power initiated by an individual that results in, or has a high likelihood of resulting in, physical or psychological injury or death”. We operationalized the definition to include the following types of violent behavior during the adolescent years: murder or homicide, aggravated assault, non-aggravated assault, rape or sexual assault, robbery, gang fight, physical aggression, psychological injury or harm, and other serious injury or harm. By selecting this definition and limiting our focus to violence that was perpetrated by youth, we did not review the growing literature that relates to suicide, verbal aggression, bullying, weapon carrying, externalizing behaviors (e.g., acting out), attitudes about violent behavior, and intent to commit violence. Moreover, we did not review literature related to youth crime against property or materials (such as burglary, theft, vandalism, arson). These violence-related behaviors and attitudes were included in this review only to the extent that they appear in the literature as risk factors for violence.

Based on the CDC's definition, we reviewed interventions that examined only changes in youth violence as an outcome. Consequently, we did not review intervention research that analyzed only other related outcomes such as conflict resolution or negotiation skills, attitudes about violence, bonding with school, or relationships with pro-social peers.

Given the scope of the Task Order, we also chose to limit our focus to address violence as perpetrated by adolescents, ages 12 through 17 years. No universally accepted age definition of adolescence exists. While there is consensus that adolescence is the period between childhood and adulthood, some experts believe that adolescence ends with the age of majority, 18, while others extend adolescence to age 19, 21, or 24. Because of our chosen age parameters, we did not review the literature that describes violence perpetrated by children and pre-adolescents, nor did we review the literature related to violence perpetrated by those we defined as young adults, i.e. those 18 and over. In addition, we included early childhood interventions designed to reduce violence only if they include outcomes reported during adolescence.

Given our limited time and resources, we needed to further limit our evidence review to include only peer-reviewed published articles and articles retrievable by four search engines - MEDLINE®, PsychInfo, SocioAbstracts, and ERIC. We also decided to include only articles that were published in 1990 or later, recognizing that by doing so, we would exclude a considerable segment of the literature. Also excluded were published findings from research conducted outside the United States. To be sure, awareness is growing that violence, including youth violence, is a global problem. Examining risk and protective factors identified within other regions and countries, and using these data to make international comparisons, would no doubt be an interesting and important endeavor. Unfortunately, such comparisons were outside the scope of this review.

Finally, we made the decision to limit our review to prospective longitudinal cohort studies to examine the evidence on risk and protective factors associated with youth violence. This decision was scientifically driven and made in an effort to ensure that our review was focused on the highest quality and most current literature. To be sure, the numerous cross sectional studies that have been conducted related to youth violence may shed light on risk factors that are worthy of further study. However, longitudinal studies of the same individuals have the greatest power to reveal possible risk and protective factors for and to test the effects of interventions on subsequent outcomes.

In this chapter, we provide a discussion of the findings from this evidence review according to each of the key questions, including a discussion of the methodological challenges inherent in performing this type of evidence review for such a topic. From this discussion, we offer a set of recommendations for future research priorities (Key Questions #6).

## Risk Factors Contributing to Youth Violence (Key Questions #1 and #2)

Because few studies examined a comparable set of risk factors (i.e., many risk factors were examined only by a single study), our ability to draw conclusions based on the available evidence was limited. Across all studies, only one risk factor, male gender, was consistently reported as being significantly associated with youth violence perpetration. As an independent factor, low family SES was consistently reported not to be associated with youth violence; however, the co-existence of low SES with other potential risk factors increased the risk of youth violence. No other potential risk factors were consistently associated with increasing the risk for youth violence.

Among studies that specifically focused on adolescent males, we identified a consistent association between violence and anger, cigarette smoking, and non-violent delinquency. For adolescent females, we consistently identified a significant association between violence and non-violent delinquency. For research conducted with at-risk youth populations, being Latino was consistently associated with repeated physical aggression among adolescent males; no consistent findings were identified for research conducted with at-risk adolescent females.

Our attempt to draw conclusions from the literature regarding risk factors for youth violence has raised more questions than it answers. Methodological, analytical, and other issues limit our ability to derive conclusive findings from existing studies. In the following sections, we outline some of these issues to elucidate the challenges that the scientific and policy community must face to truly understand the antecedents to youth violence.

### Issues Challenging Analysis of the Data

Definition of violence as an outcome variable. While this evidence review selected and included only studies that examined perpetration of violence as a primary outcome, we saw no uniformity in how violence was defined and measured. Some studies restricted their definition and measure of violence to physical assault, while others clustered homicide, rape/sexual assault, and other types of assault together. Additionally, studies often used different conceptual and theoretical models to guide and inform their research, as well as different approaches to measuring and analyzing these data. In this review, we treated all outcome measures equally, whether studied individually or as an aggregate. Thus, we were not able to examine the individual risk factors associated with each specific form of violence (e.g., fighting versus homicide versus sexual assault). Ideally, with sufficient power, one would examine the various risk factors associated with each form of violence, and then examine the types of risk factors that are common to or shared across the various forms of violence.

Co-occurring versus independent predictors. The intent and the analytical implication of Key Question # 1 was distinct from those of Key Question #2. While we were looking for independent predictor(s) for youth violence in Key Question #1, we were looking for dependent risk or protective factors that occurred simultaneously in Key Question #2. In our review for Key Question #1, we reported the findings from multivariate models that controlled or adjusted for the effect of other factors included in the models. For Key Question #2, we reported the findings that occurred simultaneously as a cluster. Different from the independent predictors identified in Key Question #1, the factors in a cluster that occurred simultaneously were likely to be highly correlated. Frequently, a factor found statistically significant in a univariate or bivariate analysis was found non-significant after adjusting for other factors in the model. For example, Herrenkohl and colleagues (Herrenkohl, Egolf, 1997; Herrenkohl, Guo, 2001) reported a significant influence of SES in bivariate analysis using data from the Lehigh longitudinal study in 1976 and data from the Seattle Social Development Project in 2001, but the influence of SES was not statistically significant after controlling for the influence of other factors in multivariate analysis. Until both the dependent and independent nature of the risk and protective factors are properly assessed and clearly differentiated, controversies regarding the significance or non-significance of those factors will persist.

Non-significant findings. In analyzing the literature to identify independent risk- and protective factors, some factors were consistently found not to be associated with violence. A factor could be found not to be significantly predictive of violence for either of two reasons: either the factor is truly not associated with later violence or it has not heretofore been possible to conduct a study that allows the association to be measured. A factor may or may not appear to be meaningful or significant, depending on whether researchers are interested in identifying independent predictor(s) or dependent predictors that occur simultaneously, that is, whether univariate or bivariate analysis or multivariate analysis is conducted, as discussed above. From an analytical perspective, the non-significance of a finding might be related to sample size and power. Non-significance could be related to small sample size or inadequate power to detect a significant difference. Thus, a non-significant finding in a study with a small sample size may not eliminate the potential importance of a risk factor.

Heterogeneity of study populations and designs. For research syntheses, the number and heterogeneity of studies that assess the same or similar populations becomes important. That is, if the study populations, conditions, independent variables, outcomes, and original method of analysis are sufficiently different, attempting to draw meaningful conclusions from combined data can become difficult. For the current analysis, heterogeneity in both study populations and study characteristics (including dependent variables) limited the numbers of studies whose data could be compared, thus challenging our attempts to discern potentially significant factors.

Risk factor definitions, measures and analysis. Another analytical issue relates to cross-study differences in the definition, measurement, and analysis of risk factors. Major differences were identified in the operational definitions and measurements of risk and protective factors across most of the studies we reviewed. Thus, meta-analytic techniques could not be used to pool those risk/protective factors across the various studies. Such differences have no doubt contributed to some of the confusion that currently exists within the field. For the current evidence assessment, the differential grouping of several factors into constructs presented a problem. For example, some studies considered “alcohol and other drug use” as a risk factor while others considered “illicit drug use”. This made it difficult to decide whether findings for them should be pooled because when factors were grouped into domains or constructs, the subtlety and/or uniqueness of individual factors might be lost. In our assessment, we used the factors as defined in the articles with no attempts to combine them into constructs. This may present difficulties in interpretation when one attempts to compare our findings with those in other reviews.

### Challenges with Interpretations of Specific Findings

The issues and challenges described above have a significant impact on the interpretation of our findings related to key constructs of interest such as SES, age, and race/ethnicity. The demographic constructs are of interest to the Conference Panel as indicated in Key Questions #4. The socio-economic indicator is of interest as it has been shown to be a confounding factor in racial differences in homicide rates (Hennes, 1998).

Socio-economic status (SES). As we noted earlier, low SES or low family income was not consistently reported as a significant independent risk factor for youth violence. One reason could be that we included only studies that expressly used the term SES rather than including studies of factors such as low parental education or unstable financial base. Therefore, if a study reported that low parental education was a predictor but low SES was not, we reported them as two separate findings. We did not investigate whether the finding would be the same if we combined findings for participants with low parental education and those with low SES as a predictor.

Another reason that low SES was found not to be an independent significant risk factor for youth violence was that, as mentioned, the effect disappeared with multivariate analysis when other confounding factors were taken into consideration (Saner and Ellickson, 1996; Brezina, 1999; Herrenkohl, Egolf, 1997; Herrenkohl, Guo, 2001; Herrera and McCloskey, 2001).

Age. The findings on the effect of age were mixed, depending on many clinical and analytical factors. A significant effect of age was found in two cohort studies but not in seven other cohort studies when all population groups were combined. One study found age to be significant with bivariate analysis but not multivariate analysis (Herrenkohl, Egolf, 1997). A cohort study that examined risk factors from age six through 12 reported that age was a significant factor among boys but not girls (Becker and McCloskey, 2002, Herrenkohl, Hill, 2003). Another study that examined the role of childhood abuse and neglect in violence (Rivera and Widom, 1990) found that age was a significant factor for adult but not juvenile violent crimes. In a study that examined the risk factors for dating violence perpetration (Foshee, Bauman, 2001), age was not reported as a significant risk factor for either boys or girls. However, because the study used a follow-up period of only one year, the true impact of age could not be determined. In a study that examined repeated violent behavior in boys (Beyers, Loeber, 2001), age was found to be a significant risk factor in low SES areas but not in high SES areas. However, this effect disappeared with multivariate analysis.

Race/ethnicity. Findings regarding the effect of race/ethnicity should also be interpreted with caution. Across all study types, all types of violent behaviors, and all study populations, Latino ethnicity was reported as a significant risk factor in four of seven cohort studies. And those studies that found an effect for Latino ethnicity were no more homogeneous than those that did not. Thus, no real conclusions can be drawn from the existing studies regarding the effect of race or ethnicity as a risk or protective factor.

The following series of findings illustrate the difficulties we faced in generalizing results from studies with different outcome measures of violence. In a large longitudinal cohort study for the general population when only fighting was considered as the violent behavior, being Latino was not a significant risk factor (McNulty and Bellair, 2003). In the article by Loeber et al. (Loeber, Wei, 1999) that reported findings on at-risk boys from three cohort studies, the findings on being Latino were mixed. When “fighting” was considered as the violent behavior, being Latino was a significant risk factor in one cohort study but not in another. When “rape, attack, and strongarm” were considered as the violent behaviors, being Latino was reported as a risk factor in both cohort studies. In another large cohort study for the general population, being Latino was reported as a significant risk factor among boys but not among girls (Dornbusch, Lin, 1999) when interpersonal violence perpetration was the outcome. Lastly, in a large study for inner-city male adolescents, where race/ethnicity was defined more specifically as Cuban, non-Cuban Hispanic, American Black, White, Haitian, Caribbean Black, Nicaraguan, and others (Kingery, Biafora, 1996), being Latino (Cuban or non-Cuban Hispanic) was not reported as a significant risk factor for “gang fights,” “using force to get money or items,” or “beating someone for no reason.” In this study, being Caribbean Black and Nicaraguan were found to be risk factors for these violent behaviors. In a study for at-risk boys, being Latino was not reported as a significant risk factor for repeated violent delinquency either in high SES or low SES areas (Beyers, Loeber, 2001). These mixed findings for race/ethnicity illustrate the difficulties in combining and/or interpreting findings from different studies.

## Effectiveness of Interventions for Youth Violence (Key Question #3)

Disregarding study design, we identified 16 articles that addressed 15 primary interventions, 11 articles that addressed 10 secondary interventions, and seven articles that addressed seven tertiary interventions. Thirteen of these studies were RCTs: five (37.5 percent) assessed primary interventions, six (46 percent) assessed secondary interventions, and two (15 percent) assessed tertiary interventions. Focusing only on these RCTs, one of five (20 percent) primary interventions, three of six (50 percent) secondary interventions, and two of two (100 percent) tertiary interventions were effective.

In general, this increasing effectiveness with increasing level of intervention is not unexpected. The overarching goal of most primary prevention interventions is to reduce risk behaviors that have been observed under some conditions to lead to violence. Therefore, their outcome indicators focus primarily on reduction of potential risk behaviors, such as use of illicit drugs. In contrast, the target populations for secondary and tertiary interventions to reduce violent behavior (or any behavior) are those already at heightened risk for or already engaging in the behavior. Thus the goal of those interventions, particularly tertiary interventions is more likely to be reduction in violence outcomes, the focus of our analysis. We considered an intervention effective only if it was associated with a reduction in violence outcome(s), not if it merely reduced risk behaviors. Therefore, our findings for primary interventions should be interpreted in light of this contrast. What is more, a tertiary intervention is more likely to be successful than a primary intervention, because the target population is small and homogeneous with respect to prior engagement in the behavior of interest, compared with the population for a primary intervention.

In many of the RCTs we reviewed, although the unit of analysis was the individual subject, the unit of randomization was frequently not the individual subject but an aggregated unit of individuals, such as a school, team, homeroom, family, or youth bureau. This inadequacy in randomization results in inherent differences between the experimental group and the control group of subjects as was evidenced by the need for eight of the 13 RCTs to adjust for differences in the characteristics of the two groups in analysis. Further, cross-contamination can occur in group-randomized controlled trials that can influence the apparent effectiveness of programs. However, RCTs that enroll individual participants are extremely difficult to implement in “real world” settings, especially in the behavioral and social sciences; thus, group RCTs are frequently used instead. Therefore, more research should be focused on the design, implementation, and analysis of group RCTs to increase their scientific rigor. For example, the question of what is a sufficient number of groups to detect a minimum level of group difference needs to be addressed, as does the question of how to rigorously analyze the effectiveness of interventions where the group is the target of the intervention and where there are likely to be important group effects. Research in this area will contribute greatly to the rigor of the methods used in the social sciences.

## Program Effectiveness by Age, Gender, and Race/Ethnicity (Key Question #4)

Similar to our assessment with the level of interventions, within study comparisons are the strongest analytic approach to answer this question. However, none of the studies provided the information needed to evaluate differential effects by age, gender, or race/ethnicity. Thus we resorted to the use of the “vote-counting” method (see Chapter 2) to summarize the findings.

Effect of age. The focus of this assessment was on violence perpetrated by adolescents, 12 through 17. Thus, we limited our review to published articles that reported intervention effectiveness in this age range. Because of the small number of studies identified, we did not subdivide the data for the 12 through 17 age range into smaller ranges.

Effect of gender. To assess the effect of gender on program effectiveness, we combined all types of study designs, using only studies that reported the gender distribution of their study subjects. Of the 21 studies that assessed effectiveness for both males and females, nine demonstrated effectiveness (43 percent), compared with two of four studies (50 percent) that enrolled only males. Among the five studies that presented findings for males and females separately, all but one found that the effectiveness of the interventions was the same for both genders; the one exception was a NRCT of a secondary prevention intervention.

Effect of race/ethnicity. For race/ethnicity, when we used the predominant ethnic group as the reference and combined all study designs, the effectiveness of interventions was found to be ethnic-specific: three in 10 (30 percent) studies with predominantly Caucasian subjects, nine in 12 (75 percent) studies with predominantly African-American subjects, and none (0 percent) of the two studies with predominantly Latino subjects. Due to the small number of studies, these statistics should be viewed as descriptive in nature.

## Commonalities of the Interventions That Are Effective, and Those That Are Ineffective (Key Question #5)

Similar to the assessment of effectiveness by gender and racial/ethnic groups, it is impossible to draw any conclusions about relative effectiveness of the interventions by program characteristics, because no one study explicitly compared effectiveness by characteristics of the interventions.

The most important characteristic that differentiated the effectiveness of the interventions was the level of the intervention - i.e., whether it was primary, secondary, or tertiary. Based on our analysis of the RCTs, effectiveness was reported in one of five (20 percent) primary interventions, three of six (50 percent) secondary interventions and two of two (100 percent) tertiary interventions. Although the number of studies is too small for statistical significance and although the results were based on the vote-counting method (see Chapter 2), the observed findings are clinically meaningful. The findings from studies using other designs are less clear than those from RCTs. Thus the type of study design might play a role in detecting program effectiveness.

Further, our finding that the effectiveness of interventions increases with the level should not be misconstrued as discrediting primary interventions. Primary interventions are frequently designed with the goal of preventing attitudes and behaviors that could lead to violence and are not directed towards reducing violence itself. Therefore, it would be more appropriate to measure population effectiveness (and use an appropriate intermediate outcome) for primary interventions rather than individual effectiveness as we have used in this review. A growing body of literature assesses the effectiveness of programs targeted to communities or neighborhoods. The efforts by developmental researchers to quantify community or neighborhood effects will no doubt contribute significantly to the evaluation of the effectiveness of primary intervention programs.

In our attempt to evaluate other characteristics of the intervention programs that might distinguish effective programs from ineffective programs, we did not observe any significant variations in intervention effectiveness according to the delivery setting, between single and multi-component interventions, among interventions of different duration, or among interventions implemented at different school levels. However, we did observe that secondary interventions that lasted a year or longer were more likely to be found effective (as reported in four of four articles) than those that lasted six months or less (as reported in five of five articles). Again, it is important to note that this analysis included only a small number of studies; thus, patterns, if any, would require further substantiation.

We believe many other characteristics of an intervention program might play a significant role in that program's effectiveness. One such characteristic is the success or failure related to the implementation of the intervention, such as the degree to which participants attended the sessions; this information was generally not reported within the articles reviewed nor consistently reported. A considerable contribution to the future literature would be the consistent reporting of intervention characteristics, as well as a description of the approach used to implement prevention interventions.

## Limitations and Priorities for Future Research (Key Question #6: What are the priorities for future research?)

Given the restricted scope of the project and the methodology required for assessing the evidence, this report can not draw many conclusions, and many of the findings are clinically intuitive (e.g. male gender as a consistent risk factor, polydrug use leading to increased violence in boys and girls, youth exposed to multiple risk factors being more likely to engage in later violence). Much of the value of this report is in the identification of the current status of research on youth violence, the existing research gaps and inconsistencies, and the need for additional scientifically rigorous studies. The inconsistent reporting of the details of various intervention programs made it essentially impossible to evaluate comparative program effectiveness by individual program characteristics.

In the following sections, we address the limitations of our analysis and priorities for future research in five specific areas: 1) risk factors contributing to youth violence, 2) intervention programs for the prevention of youth violence, 3) quality of publications, 4) rating of study quality and 5) evidence assessment methodology. At the outset, we established conceptual and analytic frameworks, i.e., a road map of causal pathways, for organizing exposure to risk and protective factors — including participation in prevention interventions — and violence outcomes. We used these constructs to identify gaps in research with respect to our ability to assess the relationship between exposure to risk/protective factors and violence outcomes.

### Risk Factors Contributing to Youth Violence

Definition, scope, and type of youth violence. As previously noted, we found little consistency in the definitions used by the various studies to define youth violence and/or violence related outcomes. Some studies defined violence according to one or more discrete behaviors, others used a composite score, while others combined related violent and non-violent behaviors in their definition of violence. Further, while we had hoped to be able to differentiate between life-threatening and non-life-threatening violence outcomes, few studies provided the information needed to make such a distinction. We believe that first and foremost, an effort needs to be made to develop some uniformity in the ways that youth violence and violence-related outcomes are both defined and operationalized, and these definitions should be incorporated into future research so that study conditions become more uniform and consistent. We therefore recommend that experts from the fields of psychiatry, psychology, sociology, criminal justice, public policy, and education launch a national effort to develop comparable approaches to defining, measuring, and analyzing research data related to youth violence, and that new initiatives be funded to facilitate the collection of comparable data across multiple sites, with multiple youth populations, by researchers from various theoretical orientations and disciplines. Such multi-site cooperative agreement studies would permit the use of combined prospective cohorts from which a common standardized dataset could be assembled and analyzed.

Framework for studying risk factors. While previous research has largely focused on the identification of risk factors associated with or predictive of youth violence, the ways in which risk and protective factors are defined and measured across studies and study populations show little consistency. This lack of consistency has contributed to difficulties in synthesizing findings across studies for the purpose of ultimately developing a cumulative knowledge base. Moreover, much of the research that has been conducted to examine risk factors has been conducted without a framework within which to organize and integrate the temporal and lateral co-occurrences of risk factors. Although we have observed increasing efforts in this area, such as the creation of developmental pathways, they represent only a beginning because of the difficulties inherent in longitudinal studies and the requirement for large, uniform, and comprehensive datasets for such endeavors. Considerable effort is needed in this specific area of research. An important starting point would be to convene a consensus conference with experts representing the disciplines mentioned earlier, to develop consensus on how to define, conceptually organize, and measure risk and protective factors that may be associated with youth violence.

Study designs and methods. Of the 233 studies identified as being relevant to risk factors for violence, the majority were cross-sectional studies (71 percent or 165 studies). Cross-sectional studies are important in identifying risk factors that may be associated with violence, but they do not allow assessments of developmental pathways or the temporal and/or lateral causal patterns that culminate in violence. The longitudinal cohort study design is the gold standard and the only design appropriate to draw such conclusions. The ideal design would be a natural longitudinal cohort followed from birth and through all stages of childhood and adolescent development. However, longitudinal studies present many obstacles, such as non-participation and attrition. Future research must concentrate on minimizing both non-participation and attrition. While natural longitudinal cohorts must be established, pseudo longitudinal cohorts could also be developed. This would involve the coordination of existing longitudinal cohorts focused on various stages of development, different types of study populations, and different types of outcomes in order to assemble a common dataset for analysis. Such an effort would require strong central support and cooperation from all parties involved.

Another area of future research would be to compare the findings from cross-sectional studies with that from longitudinal studies in order to identify how and in what ways findings from cross-sectional studies could be used for longitudinal research. For example, what are the risk or protective factors that could be validly obtained from cross-sectional studies and which ones could not? What are the sources of data or methods of data collection in cross-sectional studies that would produce valid information on an individual equivalent to that from longitudinal studies?

### Interventions for the Prevention of Youth Violence

Design and conduct of intervention studies. Of the 32 studies that were relevant to the key questions on interventions, only 13 (41 percent) were RCTs: five for primary prevention interventions, six for secondary prevention interventions, and two for tertiary prevention interventions.

Due to differences in the type of interventions implemented, as well as differences in the types of outcomes evaluated, we were not able to pool studies within a specific level of intervention (e.g., primary versus secondary prevention). We recommend more randomized controlled interventions at each level, as well as trials that enroll sufficient numbers of youths of both genders, the range of ages, varying race/ethnicity, and the spectrum of other characteristics thought to increase the risk of youth violence in order to permit comparative analysis.

What's more, greater effort is needed when the unit of randomization is larger than the individual to minimize differences and increase comparability of groups as well as to ensure that the appropriate analytical techniques are used to adjust for differences, if any. We encourage the use of advanced statistical techniques that allow for complex sampling schemes.

Analytic approach to study effectiveness by population subgroups or program characteristics. The analytic approach taken by researchers of these intervention studies in our review was to examine the effectiveness within each population subgroup rather than investigating the differential effectiveness between population subgroups such as gender or ethnic groups. The intent of Key Question #4 could be interpreted as either or both. If the interest of the researcher is to identify the differential effectiveness of a specific program between gender groups or among ethnic groups, then the researcher must design the study and measure the differential effectiveness of the intervention between and among the subgroups of interest. Evaluating the effectiveness within each subgroup (as most of the intervention studies that we have reviewed) does not provide the same information. Therefore, we recommend that more efforts should be placed in differentiating the two types of analytic approaches to study effectiveness, whether one is interested in within differences or between differences.

The science of intervention development and evaluation. Our finding that the description and the characterization of the intervention programs have not been consistent points to the need not only to standardize the execution and reporting of interventions but also to the need to refine the scientific approaches to translate research into practice, in our case, to translate research findings into intervention development and evaluation. Consensus building efforts are needed to identify and clarify the science related to a) the use of conceptual frameworks and causal pathways for youth violence, b) risk factors and mechanisms leading to violent outcomes, c) strategies and interventions to reduce violent outcomes, d) methodologies and scientifically grounded approaches to evaluate prevention interventions, e) the effective use of policy to reduce youth violence, and f) methodologies for evaluating such policies. We recommend that the field use the greatest scientific rigor possible, including the use of control populations and extended follow-up, to evaluate the sustained effectiveness of youth violence prevention interventions.

### Quality of Publications

We attempted to evaluate the quality of each study with a defined set of criteria. However, we were not satisfied with these evaluations because the information provided in the publications was both inconsistent and inadequate. The characteristics of a study such as the study questions, conceptual framework, study design, description of study population, randomization procedures, blinding procedures, data collection procedures and instruments, validity of data collection instruments, definition of and rationale for choice of exposure factors and outcomes, analytical approaches, statistical analysis, and publication of findings could not be properly evaluated on a consistent basis, given the information in the articles. The inadequacy of the description of these methodological issues relates to both the space restriction imposed by journals and the lack of a standard for the type and amount of information to be included in the publication. Special efforts to improve the quality of publications are encouraged.

### Rating of Study Quality

When we attempted to evaluate study quality, we found that the available instruments were not appropriate for use in the social sciences. The OMAR study quality criteria were derived primarily from clinical studies, and many are not applicable to studies of social phenomena such as youth violence. We believe that a unique set of instruments should be developed to evaluate the quality of both observational and experimental studies in the social sciences.

For prospective longitudinal studies, we have shown that a high retention rate alone is inadequate to measure sample bias. In general, the sample data on which results were based were subject to three types of bias: non-participation, lost-to-follow-up (addressed by retention rate), and missing data. Therefore, the retention rate represents only one of three components of sample bias. We believe that the participation rate, follow-up or retention rate, and proportion of participants with complete data should be considered when assessing the possibility of bias in the study sample, especially for outcomes such as violence. The risk factors that are likely to contribute to violent outcomes are also likely to contribute to non-participation, loss to follow-up, and missing data.

For intervention studies, we have shown that in a strict sense, none of the 13 RCTs evaluated in our review fulfilled all six criteria put forth by OMAR. However, we do not believe that this system of evaluating study quality truly assessed the quality of the studies we reviewed because the OMAR study quality criteria were derived primarily from clinical studies. Unlike many clinical interventions for medical conditions, youth violence interventions are often multi-faceted, involve the efforts of multiple parties (e.g., teachers, parents, school administrators, etc.), are conducted over long periods of time, and can be adversely affected by factors that cannot be anticipated, characteristics that make the studies difficult to evaluate. The nature of the interventions in social science studies can also preclude some of the methodological components critical to clinical trials. For example, many interventions are school or classroom based; thus, random assignment of individual students is not only logistically impossible but could threaten validity in other ways. Nor could randomized trials be used to evaluate the impact of a state law, given the obvious fact that individuals residing in the state cannot be randomly assigned to be subjected or not subjected to the law and the sanctions for breaking it. Even when randomized trials are possible, double blinding is not exactly relevant to some outcome measures (e.g., formal arrests made by the police). The need to develop valid instruments to evaluate the quality of studies in the social sciences is apparent.

### Evidence Assessment Methods

Finally, we would like to comment on the methods used to assess the evidence for this topic. The Southern California Evidence-based Practice Center (SC-EPC) has applied these evidence assessment methods to evaluate the literature on a variety of clinical topics in the past. This report, which represents the SC-EPC's first use of the methods to assess evidence for a social science topic, demonstrated to us that such methods have limited value in the study of youth violence. Because of the complexity of the problem, the multi-factorial nature of contributing factors, and the multiple components of violent behaviors, it was virtually impossible to identify sets of data with sufficient homogeneity to allow pooling of data using meta-analytic technique.

Another difficulty we encountered in this assessment was the inability to abstract needed data from some of the articles. For example some articles excluded information that might have permitted data pooling, some combined outcomes of interest with those of no interest, and some reported on studies with vague age limits. A large number of potentially eligible articles within our scope were excluded for reasons such as these; thus, we believe that our assessment was based on only a small subset of potentially relevant studies. Alternative approaches should be considered to assess evidence for topics such as youth violence.

To circumvent the difficulties we described, we recommend that for future systematic reviews, the use of an individual-level-data meta-analysis method be considered (Stewart and Clarke, 1995; Stewart and Parmar, 1993) to identify temporal and lateral co-occurrences of contributing factors. This approach calls for collaboration among investigators from various institutions who have been following cohorts of children prospectively, to contribute data on individual members of their cohorts. Eligible cohorts are identified based on a priori criteria. Risk factors, interventions, and outcomes of interest are also defined a priori. The unique feature of individual-level-data meta-analysis is the ability it confers to retrieve a uniform set of data directly on risk factors, characteristics of intervention, and outcome measures, case by case. This case-specific data set could then be analyzed using advanced statistical techniques such as the trajectory estimating method (Nagin and Tremblay, 1999). A meta-analysis of updated individual patient data has been found to provide the least biased and most reliable means of addressing questions that have not been satisfactorily resolved by individual studies (Stewart and Parmar, 1993). However, the quality of data and the ability for cohort investigators to collect and share relevant data are important factors in the success of this approach (Stewart and Parmar, 1993). Furthermore, when compared with meta-analysis of summary data from the literature, the individual-level-data-meta-analysis is markedly more costly in terms of data retrieval, study management, and monitoring and requires considerable forward planning and incentives for investigators to collaborate on study design, measurement procedures, data analysis, data documentation and archiving, and the sharing of data as well as recognition. The cost efficiency of meta-analysis summary data from the literature over analysis of variance of individual patient data has been shown for multiple homogeneous studies (Olkin and Sampson, 1998; Mathew and Nordstrom, 1999), such as those carried out in clinical research. However, as we have discussed, studies of topics such as youth violence are often beset by complexities that preclude the compilation of homogeneous data for meta-analysis but that increase their suitability for the individual-level-data-meta-analysis approach, despite the cost.

Another factor that complicated our use of evidence assessment methods was the decision to rely solely on published articles. This restriction precluded use of reports that summarized findings from program evaluations (which, typically, are not published as such) and which could have added to the scope and breadth of the review. . For future research and program development, it is highly recommended that a survey of federal agencies, foundations, and other appropriate entities be conducted to identify current and recent research and program evaluation activities. Producing a synthesis or summary of study-group findings and other comprehensive activities that respond to the Task Order questions might also be helpful (e.g., the Campbell Collaboration report on evidence-based criminal justice programming; the Surgeon General's report on violence; the National Research Council's Juvenile Crime/Juvenile Justice). Such a survey would provide data for the formulation of recommendations regarding the development of a national research and program development agenda.

## Summary of Notable Points on the Utility of the Report

The overarching goal of this review is to bring the greatest scientific rigor to the evaluation process to identify the highest quality research findings on the topic of youth violence. With the severely restricted scope of the project, much of the value of this report was the identification of the current status of research on youth violence, the existing research gaps and inconsistencies, and the need for additional scientifically rigorous studies. Some notable points from the review included the following:

- The need for national efforts to develop comparable definitions, measurements, and analytical techniques for research data on youth violence;
- The need to facilitate the collection of comparable data across multiple sites and with multiple youth populations;
- The need to consider the use of individual-level-data-meta-analysis to examine temporal and lateral co-occurrences of risk factors contributing to youth violence;
- The recognized need to minimize non-participation and attrition in research studies;
- The call for recognition of pseudo prospective cohorts from which a common dataset can be assembled and advanced statistical analyses can be conducted;
- The need for conceptual frameworks and causal pathways, risk factors and mechanisms, effective strategies and interventions, scientifically grounded methodologies to evaluate prevention interventions, and effective use of policy and methodologies to evaluate these policies;
- The recognition of essential elements of quality publications; and,
- The need to assess and clearly differentiate the dependent and independent nature of the risk- or protective factors contributing to youth violence perpetration.