# Results

## Overview

Of the 11,196 titles and abstracts from the initial and supplemental literature searches, 1,612 (14.4 percent) met our criteria for eligibility for retrieval and secondary review. The results of the primary screening are summarized in Table 3. The reasons for rejecting the remaining 9,584 citations are summarized in Table 4. We were able to retrieve all 1,612 full-length articles. Secondary screening resulted in the acceptance of a total of 466 (28 percent) articles for data abstraction. Of these articles, 404 addressed either the first or second key question for this evidence review (i.e., these articles examined risk factors associated with youth violence), and 66 articles addressed one of the other key questions (i.e., these articles considered outcomes associated with a violence prevention intervention). Four of the accepted articles addressed both sets of questions (i.e., risk factors for youth violence and intervention effectiveness). A summary of the reasons why the other 1,146 articles were rejected is provided in Table 5. During the abstraction process, 201 articles were rejected because, on further review, they did not provide data that could be abstracted; the study outcome was not violence as defined by the project; or the research did not address one of the evidence review's Key Questions. The reasons for rejecting articles during this tertiary review are presented in Table 6. Of the 265 remaining articles, 67 were included in our evidence assessment: 35 for the risk factor questions and 32 for the intervention questions. Figure 3 presents the screening and review process used for the task order. In the following sections, we present the findings of our analysis for each of the five Key Questions.

Table 3 Primary screening results before and after discrepancy resolution

Outcome | Before resolution | | After resolution | | % of resolution resulted in retrieval
| # | % | # | %
(A) Initial searches in April through July 2003
Retrieve | 1029 | 9.3 | 1567 | 14.4 | 32.3
Disagree | 1664 | 15.4 | 0 | 0.0
Reject | 8159 | 75.3 | 9285 | 85.6
Subtotal | 10852 | 100.0 | 10852 | 100.0
(B) Supplemental searches in November 2003
Retrieve | 33 | 9.6 | 45 | 13.1 | 85.7
Disagree | 14 | 4.1 | 0 | 0.0
Reject | 297 | 86.3 | 299 | 86.9
Subtotal | 344 | 100.0 | 344 | 100.0
(C) Combined results of initial and supplemental searches
Retrieve | 1062 | 9.5 | 1612 | 14.4 | 32.8
Disagree | 1678 | 15.0 | 0 | 0.0
Reject | 8456 | 75.5 | 9584 | 85.6
Total | 11196 | 100.0 | 11196 | 100.0

Table 4 Reasons for rejecting 9,584 titles/abstracts during primary review

Rejection reason^a^ | Number | Percent
R1: Not a study ^b^ | 3559 | 37.1
R2: Study outcome is not violence as defined | 4725 | 49.3
R3: Not a human subjects study | 15 | 0.2
R4: Not a US Study | 248 | 2.6
R5: Age of population studied is over 17 years | 514 | 5.4
R6: Study not focused on youth as perpetrators | 503 | 5.2
R7: A duplicate citation | 9 | 0.1
R8: Data not abstractable ^c^ | 0 | 0.0
R9: Does not addresses our key question(s) | 11 | 0.1
Total | 9584 | 100.0

a The first reason of rejection between the two reviewers is reflected.

b Not a study included: case report, editorial, letter, clinical practice, overview, guidelines, consensus statements, methodology, opinion, commentary, description of a program, and review.

c This rejection reason was not used until the secondary screening of full-length articles.

Table 5 Reasons for rejecting 1,146 full-length articles during secondary review

Rejection reason ^a^ | Number | Percent
R1: Not a study ^b^ | 243 | 21.2
R2: Study outcome is not violence as defined | 291 | 25.4
R3: Not a human subjects study | 1 | 0.1
R4: Not a US Study | 193 | 16.8
R5: Age of population studied is over 17 years | 144 | 12.6
R6: Study not focused on youth as perpetrators | 115 | 10.0
R7: A duplicate citation | 26 | 2.3
R8: Data not abstractable ^c^ | 92 | 8.0
R9: Does not addresses our key question(s) | 41 | 3.6
Total | 1146 | 100.0

a The first reason of rejection between the two reviewers is reflected.

b Not a study included: case report, editorial, letter, clinical practice, overview, guidelines, consensus statements, methodology, opinion, commentary, description of a program, and review.

c Either the outcome of interest (i.e. violence) or the age group of interest is embedded in the findings and cannot be pulled out. The only exception is when the outcome of an article covers an age range larger than our scope, i.e. 12–17, but the mean age is between 12–17, it will not be rejected.

Table 6 Reasons for rejecting 201 full-length articles during data abstraction

Rejection reason ^a^ | Number | Percent
R1: Not a study ^b^ | 7 | 3.5
R2: Study outcome is not violence as defined | 23 | 11.4
R3: Not a human subjects study | 0 | 0.0
R4: Not a US Study | 1 | 0.5
R5: Age of population studied is over 17 years | 4 | 2.0
R6: Study not focused on youth as perpetrators | 17 | 8.5
R7: A duplicate citation | 12 | 6.0
R8: Data not abstractable ^c^ | 83 | 41.3
R9: Does not addresses our key question(s) | 54 | 26.9
Total | 201 | 100.0

a The first reason of rejection between the two reviewers is reflected.

b Not a study included: case report, editorial, letter, clinical practice, overview, guidelines, consensus statements, methodology, opinion, commentary, description of a program, and review.

c Either the outcome of interest (i.e. violence) or the age group of interest is embedded in the findings and cannot be pulled out. The only exception is when the outcome of an article covers an age range larger than our scope, i.e. 12–17, but the mean age is between 12–17, it will not be rejected.

Figure 3. Process of screening and reviewing

## Key Question #1: What are the factors that contribute to violence and associated adverse health outcomes in childhood and adolescence?

The 35 articles that were included in our assessment reported findings from 23 prospective longitudinal cohort studies; the number of articles per cohort study ranged from 1 to 6. As pointed out in Chapter 2, we used the cohort as the unit of analysis so as to assign the same weight to studies whose findings were published in a single article and studies whose findings were published in multiple articles. A list and description of the 23 prospective cohort studies is provided in Table 7. Additional information about the study subjects and study design for each prospective study is provided in Table 8, including age, gender and race/ethnicity of the study sample, duration of follow-up assessment, the sample size used in reported statistical analyses, and the retention rates.

Table 7 Description of original cohort studies

Cohort ID# | Study name | Study purpose, description of cohort, year, frequency of contact
1 | Lehigh Longitudinal Study | The Lehigh Longitudinal Study began in the 1970's as a prospective study of children and families to examine the correlates and consequences of child maltreatment. Data were collected from multiple sources at three key developmental points for children (preschool/early childhood, middle childhood/school-age, and adolescence). Study participants were sampled from child welfare abuse and protective service programs, Head Start centers, and from child care programs in Pennsylvania. The sample included 457 children. An initial assessment of children and their families was completed in 1976-77, when children were of preschool age. A second assessment of the children and their families was completed in 1980-1982 when the children were in elementary school. A third and final assessment was completed in 1990-1992 when children were adolescents or young adults. That assessment included 416 (91%) of the original 457 children.
2 | Mother- Child Pair Study | Between 1990 and 1991, 363 mother-child pairs recruited from a mid-sized city in the Southwestern US were interviewed to assess the impact of marital violence on children's mental health and development. Participants were recruited from both battered women shelters and the community at large. Subjects included mothers who reported that they had been “abused by a partner in the past year” (n=141) and a comparison group (n=146). Children were between the ages of 6–12 at enrollment. These families were followed up during 1996-1997 and 1998-1999. While the findings are based on a convenience sample, the investigators took steps to ensure that the sample was representative of a wide range of women in the community.
3 | Seattle Social Development Project | The Seattle Social Development Project (SSDP) began in 1981 to test strategies for reducing childhood risk factors for school failure, drug abuse, and delinquency. First graders in five Seattle schools were assigned to intervention or control classrooms. Each year through the elementary grades, parents and teachers in intervention classrooms learned how to actively engage children in learning, strengthen bonding to family and school, and encourage children's positive behaviors. In 1985, when the original first graders entered the fifth grade, the panel was expanded to 808 students from 18 Seattle elementary schools. These participants and their parents have been interviewed regularly since 1985.
| | http://depts.washington.edu/ssdp/
4 | National Youth Survey | The National Youth Survey began in 1976. At that time 1,725 adolescents between the ages of 11 and 17 years old as well as one of their parents were interviewed. Participants were chosen by a scientific method designed to select individuals representative of the national population. 28 years later this study is ongoing. Now called the National Youth Survey - Family Study (participants who were once 11–17 are now 39–45), this study has followed these individuals throughout time to look at their changing attitudes, beliefs and behaviors about topics such as career goals, involvement with community and family, attitudes about violence, drugs, and social values
| | http://www.colorado.edu/ibs/NYSFS/index.html
5 | RAND Adolescent Panel Study | The RAND Adolescent Panel Study was a longitudinal study of middle (junior) high school students from California and Oregon conducted to evaluate a drug prevention program developed for middle school children. Participants were initially surveyed as seventh graders in 1985 and then, again, five years later. Rigorous tracking enabled the project to retain nearly 70 percent of the seventh grade sample over this five-year period.
| | http://www.rand.org/publications/RB/RB4547/
6 | National Longitudinal Study of Adolescent Health | The National Longitudinal Study of Adolescent Health (ADD Health) is a nationally representative study that explores the causes of health-related behaviors of adolescents in grades 7 through 12 and their outcomes in young adulthood. Add Health seeks to examine how social contexts (families, friends, peers, schools, neighborhoods, and communities) influence adolescents' health and risk behaviors. Initiated in 1994 under a grant from the National Institute of Child Health and Human Development (NICHD) with co-funding from 17 other federal agencies, Add Health is the largest, most comprehensive survey of adolescents ever undertaken. Data at the individual, family, school, and community levels were collected in two waves between 1994 and 1996. Wave I included 90,118 in-School Interviews. Wave 2 included 14,738 adolescent In-Home Interviews. In 2001 and 2002, Add Health respondents, 18 to 26 years old, were re-interviewed in a third wave to investigate the influence that adolescence has on young adulthood. Wave 3 included 15,197 young adult In-Home Interviews and biomarker collection.
| | http://www.cpc.unc.edu/addhealth
7 | Widom National Institute of Justice Study | This study was designed to explore the relationship between child abuse and neglect and violent criminal behavior. This study examined the official criminal histories of a large number of people whose sexual victimization during childhood had been validated. These victims of sexual abuse were compared to cases of physical abuse and neglect and to a control group of individuals who were closely matched in age, race, sex and appropriate family socioeconomic status. The subjects were 908 individuals who had been subjected as children to abuse (physical or sexual) or neglect, and whose cases were processed through the courts between 1967 and 1971. All were 11 years of age or younger at the time of the incident(s). The research method used a “matched cohorts” design. Both groups were followed into adolescence and young adulthood to determine if they had engaged in delinquent behavior or had committed crimes as adults. At the time they were chosen for the study, none of them had as yet engaged in delinquent or criminal behavior. The major aim of this study was to determine whether sexual abuse during childhood puts victims at greater risk for criminal behavior later in life than do other types of maltreatment.
| | http://www.ncjrs.org/pdffiles/abuse.pdf
8 | Safe Date Program | This prospective cohort study was designed to examine predictors of adolescent dating violence from several domains guided by an ecological perspective. 8^th^ and 9^th^ grade students from 14 public schools in Johnston County North Carolina were stratified by grade and matched on school size. One member of each matched school pair was randomly assigned to treatment or control condition. At baseline, 1965 enrolled. Follow up data were collected one month after the program activities and one year after program activities. An additional 5 waves of data collection were gathered later. The study began in 1994.
9 | New York Dating Violence Prevention Program | The prospective comparative cohort study was part of an intervention study in Suffolk County, NY examining dating aggression and whether or not psychological victimization at baseline predicted physical aggression (at baseline and follow-up). The sample included ethnically and racially diverse sample of male and female high school students enrolled in a mandatory health education class. The sample size was 206 (selected from sample of 2,320 students). Youth were recruited in the spring of 1995 and the study ended in the Fall of 1996.
10 | Offspring of subjects from the Houston Independent School District Study | This prospective cohort study (on the offspring of a cohort of 7th graders from Houston Independent School Districts) was used to examine the relationship between substance use, weapon carrying, and violence. A total of 5887 youth ranging from age 12 – 20 were enrolled and followed for 3 years. At the 3-year follow up, 2,222 youth and young adults were interviewed.
11 | National Education Longitudinal Survey | The National Longitudinal Education Survey of 1988 (NELS:88) is a large-scale longitudinal study of high school students conducted by the National Center for Education Statistics (NCES). Begun in 1988, it provides trend data about critical transitions experienced by 8th grade students as they progressed through high school, secondary school, and/or the work force. Data on student, parent, and teacher attitudes and behaviors, student academic performance, family, school and community background were collected. There were five rounds of data collection. Base Year (BY): 1988; 1st follow-up (FU1): 1990; 2nd follow-up (FU2): 1992; 3rd follow-up (FU3): 1994; 4th follow-up (FU4): 2000. In the base year, 26,432 students were selected for the study, and 24,599 participated. In the first follow-up, 19,363 were subsampled due to budgetary constraints.
| | http://www.wws.princeton.edu/~kling/surveys/NELS88.htm
12 | Project Northland | Project Northland is a community- wide alcohol use prevention research trial, sponsored by the National Institute on Alcohol Abuse and Alcoholism of the National Institutes of Health. Project Northland is the largest randomized community trial that has ever been conducted for the prevention of adolescent alcohol use, involving 24 school districts and 28 adjoining communities in northeastern Minnesota and the first prevention trial to systematically link and study behavioral curricula in schools, parental involvement programs, extracurricular peer leadership, and community-wide efforts for young adolescents in grades 6–8. Project Northland addresses both individual behavioral change and environmental change. Project Northland also strives to change how parents communicate with their children, how peers influence each other, and how communities respond to young adolescent alcohol use. Components include parent involvement and education programs, behavioral curricula, peer participation, and community activities. Students in the Class of 1998 from the 24 school districts were the focus of the evaluation of Project Northland. School districts and communities were randomized to intervention or reference condition in 1991. The first phase of Project Northland took place in the intervention schools and communities from 1991 to 1994. Reference schools and communities used their own programs before receiving the Project Northland programs in 1994. Project Northland involved about 2400 students in the Class of 1998 from 24 school districts in northeastern Minnesota during their 6th, 7th, and 8th grade years (1991-1994). The school districts were randomly assigned as intervention or control districts in 1991 before any surveys or programs had begun. Students and parents of the Class of 1998 were surveyed annually. Project Northland's intervention involved three years of behavioral curricula in the classrooms, parental involvement programs, extracurricular peer leadership, and community-wide task force activities. Participation in the Project Northland programs was very high in all districts and communities over the three years of the study.
| | http://www.epi.umn.edu/projectnorthland/
13 | Collaborative Perinatal Project | The National Collaborative Perinatal Project (NCPP), 1959-1974, was conducted by NIH's National Institute of Neurological Diseases and Stroke. NCPP data constitute an important resource for biomedical and behavioral research in many areas of obstetrics, perinatology, pediatrics, and developmental psychology. The data also provide a prospective base for examining neurological and neurosensory defects and the relationship of pregnancy and perinatal factors on the health of individual children. The major categories of data collected include obstetrical, pediatric, pathological, serological, socioeconomic and family, genetic history, psychological, speech, language, and hearing. The mother was examined during pregnancy, labor, and delivery. The children were given neonatal examinations and follow-up examinations at four, eight, and twelve months, and three, four, seven, and eight years. Supplemental information was gathered throughout the study, including family linkages between related women participating in the NCPP. There are 6,700 data items on the approximately 58,000 study pregnancies.
| | Among the studies conducted on subsamples of this cohort, one evaluated the impact of pre/perinatal disturbances and disadvantaged familial environment in predicting criminal violent offending. This study used an original cohort of: 2,958 and a final study cohort of 987.
| | http://www.archives.gov/research_room/center_for_electronic_records/national_institutes_of_health.html
14 | Durham Longitudinal Study | This prospective, longitudinal study examined peer rejection and aggression in childhood as predictors of the severity and type of delinquency during adolescence. Three cohorts of predominantly low socioeconomic status, urban 3^rd^ grade African American boys and girls were recruited in 1984, 1985 and 1986 for a total sample of 1,749 third graders. Youth reports of delinquency was gathered at grades 6, 8, and 10 and the most recent follow up was conducted at age 22.
15 | Pittsburgh Youth Study | The Pittsburgh Youth Study began with a random sample of boys in the first, fourth, and seventh grades of the Pittsburgh, PA, public school system. Information from the initial screening was used to select the top 30 percent of boys with the most disruptive behavior. This group of boys, together with a random sample of the remaining 70 percent who showed less disruptive behavior, became the sample for the study. The sample contains approximately 500 boys at each grade level, for a total of 1,517 boys. Each student and a primary caregiver were interviewed at 6-month intervals for the first 5 years of the study; teacher ratings of the student were also obtained. The middle sample (fourth grade) was discontinued after seven assessments. The youngest sample (first grade) and oldest sample (seventh grade) are currently being interviewed at annual intervals, with totals of 16 and 14 assessments, respectively. The study has been highly successful in retaining participants, with a retention rate of at least 85 percent for each assessment.
| | http://ojjdp.ncjrs.org/ccd/pittsburgh.html
16 | South Florida Longitudinal Study | This prospective cohort study was an investigation of factors associated with health status in the Miami area in 1990. This substudy was designed to compare race/ethnic groups on levels of violence and associated risk factors and to challenge the hypothesis that blacks are more violent than whites within a similar socio-cultural context in an urban area. Eligible subjects included all 6^th^ and 7^th^ graders from 48 middle schools in Dade County. Subjects were limited to males except in four randomly selected schools. The sample was 6,760 at baseline. Subjects were interviewed 3 times over three years from 1990 - 1993.
17 | Denver Youth Study | The Denver Youth Survey was a longitudinal study of urban youth projects supported by theOffice of Juvenile Justice and Delinquency Prevention (OJJDP) since 1986 through its Program of Research on the Causes and Correlates of Delinquency (Causes and Correlates). The Denver study followed 1,527 boys and girls from high-risk neighborhoods in Denver who were 7, 9, 11, 13, and 15 years old in 1987. The primary goal of the study was to identify social conditions, personal characteristics, and developmental patterns linked to sustained involvement in delinquency and drug use. The Denver study explored changes in the nature of delinquency and drug use from the 1970's to the 1990's. Researchers compared equivalent measures of self-reported delinquency and drug use from matched samples of the National Youth Survey* in 1979 and the Denver Youth Survey in 1991.
| | http://www.casanet.org/library/delinquency/youth-svy.htm
18 | Rochester Youth Development Study | The Rochester Youth Development Study sample consists of 1,000 students (729 boys and 271 girls) who were in the seventh and eighth grades of the Rochester NY, public schools during the spring semester of the 1988 school year. Males were oversampled because they are more likely than females to engage in serious delinquency and students from high-crime areas were oversampled based on the assumption that they are at greater risk for offending. This project is a 12- wave prospective panel study in which members of the sample and one of their parents were interviewed at 6-month intervals from 1988 to 1992 and at annual intervals from 1994 to 1996. At the end of wave 12, in spring 1997, 846 of the initial 1,000 subjects were re-interviewed (a retention rate of 85 percent); the retention rate for parents was 83 percent.
| | http://ojjdp.ncjrs.org/ccd/rochester.html
19 | Buffalo Longitudinal Study of Young Men | The Buffalo Longitudinal Survey of Young Men (BLSYM) was a five-year panel study of substance use and delinquency among 625 adolescent males. The initial group of young men was identified by telephone using a brief questionnaire. Face-to-face interviews were conducted by trained interviewers at the Research Institute on Addictions. The first wave of the BLSYM was completed in 1993.
| | http://www.ria.buffalo.edu/summaries/rib/rib981.html
20 | Youth in Transition | This dataset consists of a five-wave longitudinal study which collected individual interview and group-administered questionnaire data from a nationwide sample of young men, beginning in the fall of 1966 when they entered tenth grade, and continuing for nearly four years. The 2,213 panel members at the time of the initial survey were clustered in 87 schools. The schools and boys were selected through use of multi-stage probability sampling to provide an essentially bias-free representation of tenth-grade boys in public high schools throughout the United States. Subsequent data collections were carried out with 1,886 young men in the spring of 1968, the end of the eleventh grade for most, with 1,799 young men in the spring of 1969, just before most were graduated, and with 1,620 in June and July 1970. The initial data collection included tests of ability and academic skills, measures of family background characteristics, and a large number of “criterion” dimensions: affective states, self-concepts, values and attitudes, plans and behaviors. Most of the criterion dimensions were repeated in all four data collections. The data from this study are available to researchers.
| | http://dpls.dacc.wisc.edu/newcatalog/study.asp?tid=5454&id=419
21 | Oregon Youth Study | The Oregon Youth Study is a longitudinal study of at risk boys, their families, and their friends that utilized a passive longitudinal cohort sequential design. The study began in 1983-84 and is still on going. The sample was drawn from public schools located in the higher juvenile crime neighborhoods of a medium-sized metropolitan region in the Pacific Northwest. This study recruited at-risk boys 4^th^ grade boys and examined the link between parental discipline, antisocial behavior, and deviancy. A total of 206 boys were enrolled in the project and interviewed during 5 waves beginning when the boys were 9 and 10 and ending at age 17 and 18. The sample was predominately white. The parents in the sample were predominately working class, with a significant number of families receiving some form of unemployment or welfare assistance.
22 | White Male Study | This prospective cohort study was designed to assess the effects of pubertal changes in testosterone on sexual activity during adolescence. Several measures of aggression were also included in the study and used to analyze the influence of testosterone on aggressive behavior in adolescent males. The sample was 127 white males in 7^th^ grade were recruited from an unspecified school district in a Southeastern State. Subjects completed 5 semiannual questionnaires in their home followed by a sixth questionnaire 1 year later. Blood and saliva samples were also collected semiannually. The study lasted approximately 3 years.
23 | Iowa Family Distress and Coping Study | The Iowa Family Stress and Coping study, was designed to assess the influence of corporal punishment and witnessing parental marital violence, and the protective effects of involved supportive parenting, on the development of delinquent or antisocial behaviors and dating violence of adolescent boys. Eligible subjects were 7^th^ grade boys with 2-parent families from private and public schools in 8 counties in North Central Iowa. Youth were followed annually for 5 years. The last two waves of data collection included questions on dating violence. The initial wave included 205 boys. 163 boys participated in all 5 waves of data collection.

Table 8 Characteristics of prospective cohort studies for Key Questions #1 and #2

Cohort ID# | Prospective cohort study | Article (First author, year of publication) | Information obtained from article
| | | Gender | Race/ Ethnicity ^a^ | Age at enrollment in years | Years of follow-up | Sample size | Retention rate ^b^
1 | Lehigh Longitudinal Study 1976 | Herrenkohl, 1997 | M, F | WAA/L | 1.5 | 16 | 317 | 69%
2 | Mother-Child Pair Study | Becker, 2002 | M, F | W/AA/API/L/N | 6–12 | 6 | M: 141 | 83%
| | | | | | | F: 146
| | McCloskey, 2003 | M, F | W/AA/API/L/N | 6–12 | 9 | 295 | 82%
| | Herrera, 2003 | F | WAA/API/L/N | 6–12 | 7 | 141 | 79%
3 | Seattle Social Development Project | Herrenkohl, 2000 | M, F | W/AA/API/O | 10 | 6 | 720 | 89%
| | Huang, 2001 | M, F | W/AA/API/O | 10 | 8 | 807 | 94%
| | Herrenkohl, 2001 | M, F | W/AA/API/O | 10 | 8 | 808 | 94%
| | Herrenkohl, 2003 | M, F | W/AA/O | 10 | 8 | 154 | 94%
4 | National Youth Survey 1976 | Roitberg, 1995 | M, F | M | 11–17 | 5 | 1494 | 87%
5 | Rand Adolescent Panel Study | Saner, 1996 | M, F | W/AA/API/L/O | 12 | 6 | 4586 | 70%
| | Ellickson, 2001 | M, F | W/AA/API/L/O | 12 | 5 | 4327 | 66%
| | Ellickson, 2003 | M, F | W/AA/API/L/O | 12 | 5 | 4265 | 67%
6 | National Longitudinal Study of Adolescent Health (ADD Health) | Dornbusch, 1999 | M, F | M | 12–17 | 1 | M: 5329 | 65%
| | | | | | | F: 3904
| | Borowsky, 2002 | M, F | M | 12–17 | 1 | M: 6800 | 71%
| | | | | | | F: 4981
7 | Widom National Institute of Justice Study | Rivera, 1990 | M, F | W/AA | 0–11 ^c^ | 20–26 | 908 | 79%
8 | Safe Date Program | Foshee, 2001 | M, F | W/O | 13–14 | 1 | M: 402 | 90%
| | | | | | | F: 529
9 | New York Dating Violence Prevention Program | O'Leary, 2003 | M, F | W/AA/API/L/O | 14–17 | 1 | M: 86 | NG
| | | | | | | F: 120
10 | Offspring of subjects from the Houston Independent School District Study | Kaplan, 2001 | M, F | W/AA/API/L | 12 | 3 | 2138 | 38%
11 | National Education Longitudinal Survey | McNulty, 2003 | M, F | W/AA/API/L/N/O | 13 | 4 | 14358 | 66%
12 | Project Northland | Komro, 1999 | M, F | W/N/O | 13–14 | 1 | 937 | 86%
13 | Collaborative Perinatal Project | Piquero, 1999 | M, F | AA | 0 | 22 | 867 | 33%
14 | Durham Longitudinal Study | Miller-Johnson, 1999 | M, F | AA | 8 | 7 | M: 164 | 73%
| | | | | | | F: 163
15 | Pittsburgh Youth Study | Loeber, 1993 | M | W/AA | 13 | 5 | 435 | 86%
| | Zhang, 1997 | M | W/AA/O | 6–12 | 4 | 1517 | NG
| | Loeber, 1999 | M | W/AA | 13 | 5 | 365 | 72%
| | Beyers, 2001 | M | W/AA | 13 | 5 | 420 | 83%
| | Stouthamer-Loeber, 2001 | M | W/AA | 13 | 5 | 506 | NG
| | Stouthamer-Loeber, 2002 | M | W/AA | 13 | 5 | 470 | 100%
16 | South Florida Longitudinal Study | Kingery, 1996 | M | W/AA/L/M/O | 11–12 | 2–3 | 3228 | 59%
17 | Denver Youth Survey | Loeber, 1999 | M | W/AA/L/O | 11–15 | 5 | 373 | 80%
18 | Rochester Youth Development Study | Loeber, 1999 | M | W/AA/L | 11–12 | 4.5 | 562 | 77%
19 | Buffalo Longitudinal Study of Young Men | Welte, 1998 | M | W/AA/O | 16–19 | 1.5 | 568 | 95%
20 | Youth in Transition | Felson, 1992 | M | NG | 15 | 1.5 | 1886 | 85%
| | Brezina, 1999 | M | NG | 15 | 1 | 1519 | 85%
21 | Oregon Youth Study | Dishion, 1997 | M | W | 9–10 | 8 | 195 | 95%
22 | White Male Study | Halpern, 1993 | M | W | 12–13 | 3 | 64–81 | 79%
23 | Iowa Family Distress and Coping Study | Simons, 1998 | M | W | 13 | 5 | 113 | 79.5%

a AA=African-American; API=Asian or Pacific Islander; L=Latino; M=Multiple; N=Native American; O=Other; W=Caucasian.

b NG=Information not given.

As noted in Table 8, the 23 cohort studies showed considerable variability with respect to the age at which subjects were first enrolled in the study, ranging from birth to 19 years; the duration of follow-up, which ranged from 1 to 18 years; the sample size, which varied from 86 to 14,358 subjects; and the retention rate, which ranged from a low of 33 percent to a high of 100 percent. We categorized the prospective studies according to sample characteristics, including population types (general population of children or adolescents vs. an at-risk population), gender, and racial/ethnic group; this information is summarized in Table 9. Table 10 summarizes the various outcomes reported in each of the published articles by type of study population, the setting from which subjects were recruited, and sample size.

Table 9 Cohort studies and articles by study population

Population type | Gender | Race/Ethnicity | Population group# | Cohort ID# | Articles ID# | Total sample size
General Population | Male & Female | Multiple | A-1 | 4, 5, 10, 11, 12 | 395, 1573, 6638, 7662, 9629, 10619, 11065 | 23,597
| Male | Multiple | A-2 | 5, 6, 8, 9, 20 | 37, 395, 634, 1573, 5303, 5704, 5894, 11087 | 11,284
| | African-American | A-3 | 14 | 7114 | 164
| | White | A-4 | 22, 23 | 6213, 7870 | 191
| Female | Multiple | A-5 | 5, 6, 8, 9 | 37, 395, 634, 1573, 5704, 9629, 11087 | 8,106
| | African-American | A-6 | 14 | 7114 | 163
At-Risk Population^a^ | Male & Female | Multiple | B-1 | 1, 2, 3, 7 | 1029, 2658, 2660, 6306, 7020, 8540, 10990 | 2,345 – 2,998
| | African-American | B-2 | 13 | 7453 | 867
| Male | Multiple | B-3 | 2, 6, 15, 16, 17, 18, 19 | 37, 1529, 4495, 4815, 5149, 6595, 6855, 8011, 9447, 9560 | 7,081 – 8,107
| | White | B-4 | 21 | 5689 | 195
| Female | Multiple | B-5 | 2, 6 | 37, 5149, 10991 | 1,520

a At-risk population included maltreated children, children of abused mothers, delinquent youth, youth considered high risk for aggression or violence, youth from high risk or high crime area, youth from high or low socioeconomic neighborhood, and youth who repeated a grade,

Table 10 Study outcome descriptor for various study populations and recruitment settings

Study outcome descriptor | Type of at-risk population | Recruitment setting | Age at enrollment | Sample size | Cohort ID# | Articles ID#
(A) General population
A-1: Male and Female, Multiple Race/Ethnicity
Fighting | | Children of subjects in earlier study recruited from junior high schools | 12 | 2222 | 10 | 10619
Fighting | | Middle and high schools | 13 | 14358 | 11 | 11065
Persistent hitting | | Middle schools | 12 | 4586 | 5 | 395
Relational violence | | Middle schools | 12 | 4327 | 5 | 1573, 9629
Hitting or beating up someone | | Middle and high school districts | 13–14 | 937 | 12 | 6638
Felony assault ^a^ | | Households | 11–17 | 1494 | 4 | 7662
A-2: Male, Multiple Race/Ethnicity
Persistent hitting | | Middle schools | 12 | 2110 | 5 | 395, 1573
Physical aggression toward parent | | High schools | 15 | 1886 | 20 | 5303
Physical violence ^b^ | | High schools | 15 | 1886 | 20 | 5894
Dating violence perpetration | | Public schools (8th or 9th grade) | 13–14 | 402 | 8 | 634
Physical aggression (partner focused aggression) | | High schools | 14–17 | 86 | 9 | 11087
Interpersonal violence perpetration ^c^ | | High schools | 12–17 | 6800 | 6 | 37, 5704
A-3: Male, African-American
Felony assault | | Elementary schools | 8 | 164 | 14 | 7114
Minor assault | | Elementary schools | 8 | 164 | 14 | 7114
Robbery | | Elementary schools | 8 | 164 | 14 | 7114
A-4: Male, White
Fighting | | A County school district | 12–13 | 78 | 22 | 6213
Dating violence | | Public or private schools (7th grade) | 12–15 | 113 | 23 | 7870
A-5: Female, Multiple Race/Ethnicity
Persistent hitting | | Middle schools | 12 | 2476 | 5 | 395
Relational violence | | Middle schools | 12 | 2329 | 5 | 1573, 9629
Dating violence perpetration | | Public schools (8th or 9th grade) | 13–14 | 529 | 8 | 634
Dating aggression | | High schools | 14–17 | 120 | 9 | 11087
Violent behavior ^d^ | | High schools | 12–17 | 4981 | 6 | 37, 5704
Felony assault | | Elementary schools | 8 | 163 | 14 | 7114
Minor assault | | Elementary schools | 8 | 163 | 14 | 7114
Robbery | | Elementary schools | 8 | 163 | 14 | 7114
A-6: Female, African-American
Felony assault | | Elementary schools | 8 | 164 | 14 | 7114
Minor assault | | Elementary schools | 8 | 164 | 14 | 7114
Robbery | | Elementary schools | 8 | 164 | 14 | 7114
(B) At-Risk Population
B-1: Male and Female, Multiple Race/Ethnicity
Aggression to same sex peers | Abused mother | Community and battered women shelters | 6–12 | 295 | 2 | 7020
Dating aggression ^e^ | Abused mother | Community and battered women shelters | 6–12 | 292 | 2 | 7020
Violence against parents | Abused mother | Community and battered women shelters | 6–12 | 267 | 2 | 7020
Violent behavior at age 18 ^f^ | High crime area | Elementary schools | 10 | 807 | 3 | 8540
Violent behavior at age 18 ^g^ | High crime area | Elementary schools | 10 | 760, 154 | 3 | 2660, 10990
Violent behavior at age 18 ^h^ | High crime area | Elementary schools | 10 | 760 | 3 | 6306
Assaultive behaviors ^i^ | Maltreated | Child welfare agencies, Head Start programs, day care programs, and private nursery schools. | 1.5 | 317 | 1 | 2658
Juvenile violent criminal behavior | Abused children | Records of the juvenile court and the adult criminal court | 0–11 | 1575 | 7 | 1029
B-2: Male and Female, African-American
Violent offending | High risk area | Hospital | 0 | 867 | 13 | 7453
B-3: Male, Multiple Race/Ethnicity
Fighting | At risk boys | Public schools and households | 12 | 500 | 15 | 4495, 6855, 9560
Fighting | High risk area | Public schools and households | 11–15 | 373 | 17 | 6855
Fighting | High crime area | Public schools and households | 12–13 | 562 | 18 | 6855
Gang fight | Inner city | Middle schools | 11–12 | 3955 | 16 | 6595
Used force to get things | Inner city | Middle schools | 11–12 | 3955 | 16 | 6595
Beat up someone for no reason | Inner city | Middle schools | 11–12 | 3955 | 16 | 6595
Violence ^j^ | At risk boys | Public schools | 12 | 500 | 15 | 4495, 6855, 8011, 9560
Violence ^j^ | High risk area | Public schools and households | 11–15 | 373 | 17 | 6855
Violence ^j^ | High crime area | Public schools and households | 12–13 | 562 | 18 | 6855
Fighting and violence ^k^ | At risk boys | Public schools and households | 12 | 365 | 15 | 6855, 9560
Fighting and violence ^k^ | High crime area | Public schools and households | 12–13 | 562 | 18 | 6855
Violent delinquency ^l^ | Abused mother | Community and battered women shelters | 6–12 | 141 | 2 | 5149
Interpersonal violence perpetration ^m^ | Repeated a grade | High schools | 12–17 | 1891 | 6 | 37
Violent offending ^n^ | Delinquent boys | A city and surrounding suburbs | 16–19 | 596 | 19 | 4815
Serious violence ^o^ | At risk boys | Public schools | 6, 9, 12 | 500 | 15 | 9447
Violent delinquency ^p^ | High SES area | Public schools | 13 | 159 | 15 | 1529
Violent delinquency ^p^ | Low SES area | Public schools | 13 | 261 | 15 | 1529
Violent delinquency ^p^ | At risk boys, high and low SES area | Public schools | 13 | 420 | 15 | 1529
B-4: Male, White
Self-reported violence ^r^ | High crime area | Public schools | 13 | 195 | 21 | 5689
Arrested Violence ^r^ | High crime area | Public schools | 13 | 195 | 21 | 5689
B-5: Female, Multiple Race/Ethnicity
Violent delinquency ^l^ | Abused mother | Community and battered women shelters | 6–12 | 146 | 2 | 5149, 10991
Violence against parents ^q^ | Abused mother | Community and battered women shelters | 6–12 | 141 | 2 | 10991
Interpersonal violence perpetration ^m^ | Repeated a grade | High schools | 12–17 | 1374 | 6 | 37

a Included aggravated assault, gang fighting, sexual assault.

b Based on 8 items, 4 were provided in the article: threatened or hurt someone, hit parents or teachers, engaged in gang fights, or used weapons)

c Got into serious fight, participation in group fight, hurt someone badly enough to require medical care, fighting resulted in personal injury, threaten with weapon, pulled a weapon on someone, use weapon in a fight, shot or stabbed someone.

d Included: Got into serious fight, participation in group fight, hurt someone badly enough to require medical care, fighting resulted in personal injury, threaten with weapon, pulled a weapon on someone, use weapon in a fight, shot or stabbed someone.

e Definition different for boys and girls; see definition table for details.

f The 4 items are: picking a fight with someone; hitting someone with intent to hurt; beating someone so badly that required medical attention; and threatening someone with a gun.

g The 6 items are: hit a teacher, picked a fight, hit someone with intent to hurt, threatened someone with a weapon, used force or threats of force to get things from others, beat someone so badly that required medical attention. Three or more acts each required before a youth was identified as having committed a violent act.

h 7 items: same as c with “hit a parent” added to the list.

i 5 of 7 items provided in the article: involved in gang fight, hitting parents or others, hitting with idea to seriously injure or kill, having sexual relations with someone against his/her will, using force or strong-arm methods to get money or things from people.

j Referred to the “violence” step in the overt pathway that included attacking someone, strong-arming, and forcing sex.

k This included the fighting step and violence step of the overt pathway. Fighting included physical fighting and gang fighting.

l 5 items: threatened someone with a weapon, hurt someone badly enough that required medical attention, threatened to hurt people, got in many fights, physically attacked people.

m The 8 items included: got into serious fight, participation in group fight, hurt someone badly to require medical care, fighting resulted in injury requiring medical care, use or threatened use of a weapon, pulled a knife or gun on someone, use of weapon in fight, shot or stabbed someone.

n The 5 items included: robbery, rape, gang fights, simple and aggravated assault.

o The 2 categories are: severely attacking or hurting people with a weapon, strong-arming; and severely attacking or hurting people with a weapon, strong-arming, gang fighting, killing.

p The 5 items are: attacked another with a weapon or with intent to seriously hurt or kill; used a weapon, force, or strong-arm method to get something from someone; physically hurt or threatened to hurt someone to get them to have sex; had sex with someone against their will; and Used force or strong-arm methods to get something from another student.

q Included: thrown something in anger; hit or pushed parent; physically threatened parent.

r This article distinguished self-reported and arrested violence. Adolescent violence referred to self-reported violence in adolescence; Violent offense referred to police contacts for violent offense including arrest assault, menacing, robbery, rape.

From the sample-size column in Table 10, we can determine the adequacy of sample size for each subpopulation. Based on the sample size and power considerations in Table 2, a cohort size of 1100 would be needed for the general population and 500 would be needed for the at-risk population, to achieve an 80 percent power to detect an odds ratio 1.5 or higher at 0.05 level of significance. Based on these thresholds, articles that deal with cohorts #8, #9, #12, #14, #22, and #23 for the general population and cohorts #1, #2, #17, and #21 for the at-risk population would not have adequate power to identify risk- or protective factors leading to youth violence. As a result, we lacked adequate statistical power for three of the six subpopulations of the general population, all of which are ethnic subpopulations (A-3: Male, African-American; A-4: Male, White; and A-6: Female, African-American. The three subpopulations with adequate power all represent multiple races/ethnicities. For the at-risk population, only two ethnic subpopulations were studied, each in a single cohort study. Subpopulation B-2, African-American males and females, studied 867 subjects and subpopulation B-4, White males, studied 195 subjects.

We then examined the other descriptor information in Table 10: outcome descriptor, recruitment setting, and age, and observed that no two prospective cohort studies were alike with respect to the type of study outcome descriptor, the recruitment setting, and the age at enrollment. Thus, we did not consider it to be scientifically sound to pool data across the heterogeneous cohort studies using meta-analysis. Instead, we summarized the study findings by population groups according to adequacy and consistency, defined as follows. First, at least two cohort studies must have reported findings for a specific risk- or protective factor: the evidence for a risk- or protective factor was considered inadequate when it was reported in only one cohort study. Second, we classified the risk- or protective factors into three categories of consistency: those consistently reported as being significantly associated with violence (defined as at least 75 percent of the studies that tested an association reporting a statistically significant result); those consistently reported as being not significantly associated with violence (similarly defined as 75 percent or more of studies); and those where studies reported mixed findings. A finding was considered to be statistically significant if the article reported a p-value of less than 0.05. In this summary, we did not use the effect size as a criterion because of the heterogeneity in the number and type of covariates or confounding factors included in the analytic model and the inconsistency in the way effect size was reported in the literature.

Using these criteria, we summarized the findings for each of the study populations that had at least two cohort studies and an adequate number of study subjects together with the combined findings for all 11 population groups (Table 11). As described in Chapter 2, we summarized the findings for each risk- or protective factor by including, first, the number of cohort studies that showed statistically significant findings, followed by the number of cohort studies that showed non-significant findings, both set off by parentheses (a finding that showed a p-value of less than 0.05 was considered statistically significant). We further summarized the findings presented in Table 11 for all study populations, the general population, and the at-risk population in Tables 12, 13, and 14, respectively.

Table 11 Summary of findings for total and six large population groups

Risk or Protective factors | All study populations combined^a^ | Study population groups with at least 2 cohort studies and adequate sample size (n=1100 for general and n=500 for at-risk populations)
| | General population | | | At-risk population
| | Male and Female | Male | Female | Male and Female | Male | Female
| 23 articles | 5 articles | 5 articles | 4 articles | 4 articles | 7 articles | 2 articles
| 35 articles | 7 articles | 8 articles | 7 articles | 7 articles | 10 articles | 3 articles
The first number in parenthesis for each cell is the number of cohorts reported a statistically significant association (p<0.05) in the article.
The second number in parenthesis is the number of cohorts that reported no statistically significant association (p≥0.05) in the article.
Individual Factors - Biological, Physical and Cognitive
Age | (2) (7) ^b, c^ | (0) (1) | (1) (1) | (1) (1) | (1) (2) ^c^ | (1) (1) | (0) (1)
Male gender | (8) (2) | (3) (1) | | | (4) (1)
White | (2) (2) | (1) (1) | (1) (0) | | | (0) (1)
African American | (5) (3) | (0) (1) | (1) (0) | (1) (0) | (1) (0) | (3) (2)
Latino | (4) (3) | (0) (1) | (1) (0) | (0) (1) | (1) (0) | (3) (1)
Asian Pacific Islander | (0) (2) | (0) (1) | (0) (1) | (0) (1)
American Indian | (1) (0) | (1) (0)
Cuban | (0) (1) | | | | | (0) (1)
Haitian | (0) (1) | | | | | (0) (1)
Carribean | (0) (1) | | | | | (0) (1)
Nicaraguan | (1) (0) | | | | | (1) (0)
Other ethnicity | (0) (2) | (0) (1) | | | | (0) (1)
Ethnicity, unspecified | (1) (1) | | (1) (0) | (1) (0) | | (0) (1)
Small physical size | (0) (1) | | (0) (1)
Testosterone levels | (0) (1) ^b^
Pubertal development | (0) (1) ^b^
Visual-motor intelligence | (0) (1) | | | | | (0) (1)
Verbal intelligence | (0) (1) | | | | | (0) (1)
Problem communicating with others | (0) (1) | | (0) (1) | (0) (1)
Skills for interactions | (1) (0) | | | | (1) (0)
Pre/perinatal disturbance | (0) (1) ^b^
Individual Factors -Emotional, Psychological and Attitudinal
Depression | (2) (2) | | (1) (1) | (0) (1) | (1) (1)
Impulsive-attention deficit or hyperactivity | (1) (2) ^c^ | | | | (1) (0) | (0) (2) ^c^ | (0) (1)
Anxiety (worrying about things) | (0) (1) | | (0) (1)
Tension (nervousness) | (1) (0) | | (1) (0)
Suicidal attempts | (1) (1) | | | (0) (1) | | (0) (1) | (1) (0)
Mental health treatment | (1) (0) | | | | | (1) (0) | (1) (0)
Anger | (2) (1) | | (2) (0) | (0) (1)
Empathy | (1) (1) | | | | (1) (1)
Jealous and controlling aggression | (1) (0) | | (1) (0) | (1) (0)
Self-esteem | (0) (1) | | (0) (1) | (0) (1) | | (1) (0) | (1) (0)
Emotional well-being | (1) (0) | | | | | (1) (0) | (1) (0)
Positive attitude toward problem behavior | (1) (1) | | | | | (1) (1)
Lack of guilt | (1) (1) ^c^ | | | | | (1) (1) ^c^
Perceived norms | (1) (1) | | (1) (0) | (0) (1)
Belief wrong to violate law | (0) (1) | (0) (1)
Perceived risk of untimely death | (1) (1) | | | | | (1) (0) | (0) (1)
Somatic symptoms | (2) (1) | | (1) (0) | | | (0) (1) | (1) (0)
Individual Factors - Behavioral
Risk-taking behavior | (1) (0) | | | | (1) (0)
Antisocial behavior | (2) (2) ^b^ | | | | (1) (1)
Conduct disorder | (0) (1) | | | | | (0) (1) | (0) (1)
Disruptive behavior (composite of ADD, ODD, CD) ^d^ | (1) (0) | | | | (1) (0)
Runaway | (1) (0) | | | | | | (1) (0)
Prosocial beliefs | (0) (1) | | | | (0) (1)
Alcohol use | (3) (1) | (2) (1) | (1) (0) | (1) (0) | | (1) (0) | (1) (0)
Alcohol/drug use | (3) (1) | (2) (0) | (0) (1) | (0) (1) | | (1) (0)
Cigarette use/smoking | (2) (1) | (1) (0) | (2) (0) | (1) (1)
Had sexual intercourse | (1) (1) | | | | | (1) (1)
General health | (1) (0) | | | | | (1) (0) | (1) (0)
Verbal aggression | (1) (0) | | (1) (0) | (1) (0)
Physical aggression | (2) (1) ^b^ | | (1) (1) | (0) (1) | | (1) (0)
Aggression ^e^ | (1) (0) | | | | | (1) (0)
Illicit drug use | (2) (3) | (1) (2) | (1) (1) | (0) (2) | | (1) (0) | (0) (1)
Selling drugs | (2) (0) | (1) (0) | (1) (0) | (1) (0) | (1) (0)
Weapon carrying | (3) (2) ^c^ | (1) (0) | (0) (1) | (0) (1) | | (1) (1) ^c^ | (1) (0)
Non-violent delinquency | (2) (0) | (1) (0) | (2) (0) | (2) (0)
Non-violent felony offense | (1) (0) | (1) (0) | (1) (0) | (1) (0)
Violent and non-violent delinquency | (1) (0) | | (1) (0)
Fighting | (2) (1) | (1) (0) | (0) (1) | (0) (1) | | (1) (0)
Serious injury/harm to others | (1) (0) | | | | | (1) (0)
Violent behavior | (2) (1) | (1) (0) | (1) (0) | (1) (0) | | (1) (1) | (1) (0)
Violence at age 10 | (1) (0) | | | | (1) (0)
Violence at age 13 | (1) (0) | | | | (1) (0)
Individual Factors - Other involvements
Religiosity ^f^ | (2) (1) | (0) (1) | (0) (1) | (1) (0) | (1) (0)
Same sex attraction | (1) (1) | | | | | (1) (0) | (0) (1)
Accept prescribed social norms | (1) (1) | | (1) (0) | (0) (1)
Perceived negative sanctions | (0) (1) | | (0) (1) | (0) (1)
Gender stereotyping | (0) (1) | | (0) (1) | (0) (1)
Pro-antisocial involvement | (1) (0) | | | | (1) (0)
Belief in moral order | (1) (0) | | | | (1) (0)
Individual Factors - Life Experiences
Victim of abuse | (0) (1) | | | | (0) (1)
Occupational strain | (1) (2) | (1) (1) | (1) (0) | (0) (1)
Victim of violence | (1) (0) | | | | | (1) (0) | (1) (0)
Death of parent(s) | (0) (1) | (0) (1) | (0) (1) | (0) (1)
Perceived difficulty of college education | (0) (1) | (0) (1)
Individual Factors - School Related
School drop-out | (0) (1) | (0) (1) | (0) (1) | (0) (1)
Truancy | (1) (0) | | | | | (1) (0) | (1) (0)
Poor academic performance | (3) (2) ^c^ | (1) (0) | (0) (1) | (1) (0) | (1) (0) ^c^ | (1) (1) | (1) (0)
Repeating a grade | (1) (0) | | (1) (0) | (1) (0)
Low school commitment | (1) (2) ^c^ | (0) (1) | | | (1) (0) | (0) (1) ^c^
School transitions | (1) (0) | | | | (1) (0)
Involvement in prosocial activity | (1) (1) | | | | (1) (1)
Bonding to school | (1) (0) | | | | (1) (0)
School functioning factor, unspecified | (1) (0) | | | | | (1) (0) | (1) (0)
Feel safe at school | (1) (1) | | | | | (0) (1) | (1) (0)
Home/Family Factors - Environment and Characteristics
Large family size | (0) (1) | (0) (1)
Low socioeconomic status or low family income | (0) (7) ^c^ | (0) (2) | (0) (2) | (0) (1) | (0) (3) ^c^ | (0) (1) | (0) (1)
Access to weapons | (1) (1) ^b^ | | | | (1) (0)
High mobility | (1) (1) | (0) (1) | (0) (1) | (0) (1) | (1) (0)
Non-Intact family structure | (2) (1) ^c^ | (0) (1) ^c^ | (1) (2) | (2) (1)
Recent separation/divorce | (0) (1) | (0) (1) | (0) (1) | (0) (1)
Remarriage | (0) (1) | (0) (1) | (0) (1) | (0) (1)
Single parent | (0) (1) | | | | | (0) (1)
Female head | (1) (1) | | (1) (0) | (0) (1)
Parent(s) age | (1) (0) | | (1) (0)
Unstable financial base | (1) (2) | (1) (1) | (0) (1) | (1) (0)
Low parental education | (1) (3) | (1) (1) | (1) (2) | (0) (3)
Social capital parent(s) | (1) (0) | (1) (0)
Family criminal behavior | (1) (0) | | | | (1) (0)
Pro-violence attitude | (2) (2) ^c^ | (0) (1) | (1) (0) | | (1) (1) ^c^
Suicidal behavior of family member | (1) (1) | | | | | (1) (0) | (0) (1)
Parent(s) drug use | (1) (1) | (1) (0) | (0) (1) | (1) (0)
Parental violence | (1) (2) | | | | (1) (2) | (0) (1) | (0) (1)
Sibling delinquency | (1) (0) | | | | (1) (0)
Poor family management | (1) (0) | | | | (1) (0)
Physical hitting between parents | (0) (1) | | (0) (1) | (0) (1)
Family conflict | (1) (0) | | | | (1) (0)
Family cohesion | (0) (1) | | | | (0) (1)
Family connectedness | (1) (2) | (0) (1) | | | (0) (1) | (1) (0) | (1) (0)
Home/Family Factors - Parent-Child Relationship
Physical abuse | (3) (2) ^b, c^ | | (1) (1) | (0) (1) | | (0) (1) | (2) (1) ^c^
Sexual abuse | (1) (2) ^b, c^ | | | | (0) (1) ^c^ | | (1) (1) ^c^
Parental supervision or monitoring | (1) (2) ^c^ | | | | | (1) (1) ^c^ | (0) (1)
Rejection by parent | (1) (0) | (1) (0) | (1) (0) | (1) (0)
Poor communication patterns | (2) (1) | (1) (0) | | | | (1) (1)
Discipline not persistent | (0) (1) | | | | | (0) (1)
Parental discipline in childhood | (0) (1) ^b , c^
Child lack involvement | (0) (1) ^c^ | | | | | (0) (1) ^c^
Positive interaction | (0) (1) ^c^ | | | | (0) (1) ^c^
Negative interaction | (1) (0) | | | | (1) (0)
Parental attachment | (2) (0) | | (1) (0) | | (1) (0)
Corporal punishment | (1) (0) ^b^
Prosocial activities | (1) (0) ^c^ | | | | (1) (0) ^c^
Reward for prosocial involvement | (1) (0) | | | | (1) (0)
Parental school expectation | (1) (1) | | | | | (1) (0) | (0) (1)
Maltreatment composite index ^g^ | (1) (0) | | | | (1) (0)
Peers
Deviant peers | (2) (1) ^b^ | | | | (1) (1)
Associate with gangs | (1) (0) | | | | (1) (0)
Delinquent or violent peers | (3) (2) ^c^ | (1) (0) | (1) (0) | (0) (1) | (1) (0) | (0) (1) ^c^
Little sense of peer connectedness | (0) (1) | (0) (1) | (0) (1) | (0) (1)
Rejected by peer status group | (1) (2) ^b^ | (0) (1)
Peer victimization | (1) (1) | | (0) (1) | (1) (0)
Peer(s) drug use | (1) (1) | (0) (1) | (0) (1) | (1) (0)
Nonconventional peers | (0) (1) | | | | | (0) (1)
Aggressive friends | (1) (0) | | (1) (0) | (1) (0)
Bad friends | (0) (1) ^c^ | | | | | (0) (1) ^c^
Suicidal behavior of friends | (1) (0) | | | | | (1) (0) | (1) (0)
School Factors
Low test scores | (0) (1) | | | | (0) (1)
Lack parental involvement | (0) (1) | (0) (1)
Approve negative behaviors | (0) (1) | (0) (1)
Community Factors
Perceived caring by adults | (1) (1) | | | | | (1) (0) | (0) (1)
Feel safe in neighborhood | (1) (0) | | | | | (1) (0) | (1) (0)
Social deprivation | (0) (1) | | | | (0) (1)
Economic deprivation | (1) (0) | | | | (1) (0)
Community disorganization | (1) (0) | | | | (1) (0)
Low neighborhood attachment | (1) (1) | | | | (1) (1)
Urban residence | (0) (2) | (0) (2)
Easy access to alcohol and drugs | (0) (1) ^c^ | | | | (0) (1) ^c^
Owner occupied housing units | (0) (1) | (0) (1)
High crime rate | (1) (0) | | | | | (1) (0)
Law enforcement against crime | (0) (1) | | | | (0) (1)
Population between 15–24 years | (0) (1) | (0) (1)
Multiple Factors
More than 5 risk factors | (1) (0) | | | | (1) (0)
4–5 risk factors | (1) (0) | | | | (1) (0)
2–3 risk factors | (1) (0) | | | | (1) (0)
0–1 risk factors | (0) (1) | | | | (0) (1)
Familial environment + pre/perinatal disturbance | (1) (0) ^b^
Multiple factors in low SES neighborhood ^h^ | (1) (0) | | | | | (1) (0)
High SES neighborhood+physical aggression | (1) (0) | | | | | (1) (0)
Low SES neighborhood+one other risk factor ^i^ | (0) (1) | | | | | (0) (1)
High SES neighborhood+one other risk factor ^j^ | (0) (1) | | | | | (0) (1)
3 protective factors vs less | (1) (0) | | | | | (1) (0) | (1) (0)
Poly drug use vs single drug use | (1) (0) | | (1) (0) | (1) (0)
Repeat physical aggression vs experimenter | (2) (0) | | | | | (2) (0)

a The total number of cohorts or articles may not equal to the sum of cohorts or articles of the study populations because of the following rules used. We counted the same findings from different articles from the same cohort only once. However, findings for different outcomes were not considered the same. We counted the same findings from different types of analysis within an article once. When the result of a finding was reported both in a bivariate analysis and a multivariate analysis in which the effects of other covariates were adjusted, the result of the finding from the multivariate analysis was used.

b Some or all of the findings were based on single cohort study on study populations not included in this table.

c Some or all of the findings were analyzed by both the bivariate and multivariate analysis. The adjusted finding(s) from multivariate analysis is(are) reported here.

d ADD=attention deficit/hyperactivity disorder; ODD=oppositional defiant disorder; CD=conduct disorder.

e Included “annoying others” and “bullying”.

f Included “religious service attendance” and “low religiosity”.

g The maltreatment composite index was based on the Maltreatment Classification System consisted of, measured on a 5-point scale, the following: physical abuse, sexual abuse, failure to provide, lack of supervision, emotional maltreatment, moral-legal maltreatment, educational maltreatment and incorrigibility.

h Low SES neighborhood + lack of guilt +had sex + carried hidden weapon + poor communication.

i Low SES neighborhood + one or combination of the following: age, impulsive-hyperactive, low school motivation, pro problem behavior, not involved, poor supervision, peer delinquency, bad friends.

j High SES neighborhood + one or combination of the following: impulsive-hyperactive, pro problem behavior, lack of guilt, had sex, peer delinquency.

Table 12 Composite Findings for All study populations^a^ 23 Cohort Studies, 35 Articles

Domain | Factors consistently reported as being associated with violence ^b^ | Factors consistently reported as being not associated with violence ^b^ | Mixed findings
Only factors with 2 or more cohorts are included
The first number in parenthesis for each cell is the number of cohorts reported a statistically significant association (p<0.05) in the article.
The second number in parenthesis is the number of cohorts that reported no statistically significant association (p≥0.05) in the article.
Individual | (8) (2) Male gender | (2) (7) Age | (2) (2) White
| (3) (1) Antisocial behavior | (0) (2) Asian Pacific Islander | (5) (3) African-American
| (3) (1) Alcohol use | (0) (2) Other ethnicity | (4) (3) Latino
| (3) (1) Alcohol/drug use | | (1) (1) Ethnicity unspecified
| (2) (0) Selling drugs | | (2) (2) Depression
| (2) (0) Non-violent delinquency | | (1) (2) Impulsive-attention deficit or hyperactivity
| (2) (0) Repeated physical aggression | | (1) (1) Suicidal attempts
| | | (2) (1) Anger
| | | (1) (1) Empathy
| | | (1) (1) Positive attitude toward problem behavior
| | | (1) (1) Lack of guilt
| | | (1) (1) Perceived norms
| | | (1) (1) Perceived risk of untimely death
| | | (2) (1) Somatic symptoms
| | | (2) (1) Cigarette use/smoking
| | | (1) (1) Had sexual intercourse
| | | (2) (1) Physical aggression
| | | (2) (3) Illicit drug use
| | | (3) (2) Weapon carrying
| | | (2) (1) Fighting
| | | (2) (1) Violent behavior
| | | (2) (1) Religiosity
| | | (1) (1) Same sex attraction
| | | (1) (1) Accept prescribed social norms
| | | (1) (2) Occupational strain
| | | (3) (2) Poor academic performance
| | | (1) (2) Low school commitment
| | | (1) (1) Feel safe at school
Home/Family | (2) (0) Parental attachment | (0) (7) Low socioeconomic status or low family income | (1) (1) Access to weapons
| | (1) (3) Low parental education | (1) (1) High mobility
| | (1) (3) Parental violence | (2) (1) Non-intact family structure
| | | (1) (1) Female head
| | | (1) (2) Unstable financial base
| | | (2) (2) Pro-violence attitude
| | | (1) (1) Suicidal behavior of family member
| | | (1) (1) Parent(s) drug use
| | | (1) (2) Family connectedness
| | | (3) (2) Physical abuse
| | | (1) (2) Sexual abuse
| | | (1) (2) Parental supervision or monitoring
| | | (2) (1) Poor communication patterns
| | | (1) (1) Parental school expectation
Peer | | | (2) (1) Deviant peers
| | | (3) (2) Delinquent or violent peers
| | | (1) (2) Rejected by peer status group
| | | (1) (1) Peer victimization
| | | (1) (1) Peer(s) drug use
Community | | (0) (2) Urban residence | (1) (1) Perceived caring by adults
| | | (1) (1) Low neighborhood attachment

a The findings in this table are presented without regard to the type of violent outcome, without regard to the age at enrollment in the cohort, without regard to the type of at-risk population, and without regard to the type of analysis. Thus, additional research is needed to assess whether these associations vary by these factors.

b Consistency here is defined as at least 75% of the cohort studies reporting a statistically significant association.

Table 13 Findings for general population

Study population | Domain | Factors consistently reported as being associated with violence ^a^ | Factors consistently reported as being not associated with violence ^a^ | Mixed findings
Only factors with 2 or more cohorts are included
The first number in parenthesis for each cell is the number of cohorts reported a statistically significant association (p<0.05) in the article.
The second number in parenthesis is the number of cohorts that reported no statistically significant association (p≥0.05) in the article.
General Population | Individual | (3) (1) Male gender | | (1) (1) White
Male and Female (5 cohort studies; 7 articles) | | (2) (0) Alcohol/drug use | | (2) (1) Alcohol use
| | | | (1) (2) Illicit drug use
| | | | (1) (1) Occupational strain
| Home/Family | | (0) (2) Low socioeconomic status or low family income | (1) (1) Unstable financial base
| | | | (1) (1) Low parental education
| Community | | (0) (2) Urban residence
General Population Male (5 cohort studies; 8 articles) | Individual | (2) (0) Anger | | (1) (1) Age
| | (2) (0) Cigarette use/smoking | | (1) (1) Depression
| | (2) (0) Non-violent delinquency | | (1) (1) Physical aggression
| | | | (1) (1) Illicit drug use
| Home/Family | | (0) (2) Low socioeconomic status or low family income | (1) (2) Non-intact family structure
| | | | (1) (2) Low parental education
| | | | (1) (1) Physical abuse
General Population Female (4 cohort studies; 7 articles) | Individual | (2) (0) Non-violent delinquency | (0) (2) Illicit drug use | (1) (1) Age
| | | | (1) (1) Cigarette use/smoking
| Home/Family | | (0) (3) Low parental education | (2) (1) Non-intact family structure

a Consistency here is defined as at least 75% of the cohort studies reporting a statistically significant association.

Table 14 Findings for the at-risk population

At-Risk population | Domain | Factors consistently reported as being associated with violence ^a^ | Factors consistently reported as being not associated with violence ^b^ | Mixed findings
Only factors with 2 or more cohorts are included
The first number in parenthesis for each cell is the number of cohorts reported a statistically significant association (p<0.05) in the article.
The second number in parenthesis is the number of cohorts that reported no statistically significant association (p≥0.05) in the article.
At-Risk Population | Individual | (4) (1) Male gender | | (1) (2) Age
Male and Female (4 cohort studies; 7 articles) | | | | (1) (1) Depression
| | | | (1) (1) Empathy
| | | | (2) (2) Antisocial behavior
| | | | (1) (1) Involvement in prosocial activity
| Home/Family | | (0) (3) Low socioeconomic status or low family income | (1) (1) Pro-violence attitude
| | | | (2) (1) Parental violence
| Peer | | | (1) (1) Deviant peers
| Community | | | (1) (1) Low neighborhood attachment
At-Risk Population | Individual | (3) (1) Latino | (0) (2) Impulsive-attention deficit/hyperactivity | (2) (1) Age
Male (7 cohort studies; 10 articles) | | (2) (0) Repeated physical aggression | | (3) (2) African-American
| | | | (1) (1) Positive attitude toward problem behavior
| | | | (1) (1) Lack of guilt
| | | | (1) (1) Had sexual intercourse
| | | | (1) (1) Weapon carrying
| | | | (1) (1) Violent behavior
| | | | (1) (1) Poor academic performance
| Home/Family | | | (1) (1) Parental supervision or monitoring
| | | | (1) (1) Poor communication patterns
At-Risk Population | Home/Family | | | (2) (1) Physical abuse
Female (2 cohort studies; 3 articles) | | | | (1) (1) Sexual abuse

a Consistency here is defined as at least 75% of the cohort studies reporting a statistically significant association.

b Firm conclusions cannot be drawn for factors consistently reported as being not associated with violence because of low statistical power and inconsistency in the definition of risk factors.

When all population groups were considered, findings for a total of 151 single factors were examined: 85 factors (56 percent) related to the individual risk domain, 40 factors (26 percent) related to the parental/familial risk domain, 11 factors (7 percent) related to the peers risk domain, three factors (2 percent) related to the school risk domain, and 12 factors (8 percent) related to the community risk domain. In addition, 12 multiple factors or pathways examined in this set of literature fell in one or more domain.

As presented in Table 12, seven individual domain risk factors were found to be consistent predictors of youth violence, including male gender, antisocial behavior, alcohol use, alcohol and drug use, drug dealing, weapon carrying, and non-violent delinquency. Of the parental/familial risk factors, only lack of parental attachment was found to be a significant predictor of youth violence. Numerous risk factors across all risk domains were either consistently not associated with youth violence or were associated only in some studies, and many of the remaining factors were examined in only one cohort study [i.e., 47 of 85 (55 percent) factors in the individual risk domain, 22 of 40 (55 percent) factors in the parental/family risk domain, six of 11 (55 percent) factors in the peer risk domain, all (100 percent) factors in the school risk domain, and nine of 12 (75 percent) factors in the community domain]. Consequently, we judged that the strength of evidence was insufficient to be able to determine the predictive power of these factors.

While Table 12 presents findings for all 11 study populations, Table 13 and Table 14 present findings for the three subpopulations with adequate sample sizes for the general population and for the at-risk population, respectively. For the general population (Table 13), findings on 48 risk or protective factors were examined from seven articles based on five cohort studies. Among the 48 factors, 10 factors (20 percent) were examined among two or more cohorts. Male gender (Komro, Williams, 1999; Roitberg and Menard, 1995; Saner and Ellickson, 1996) and alcohol or drug use (Kaplan, Tolle, 2001; Komro, Williams, 1999) were consistently significant risk factors; low socio-economic status (Roitberg and Menard, 1995; Saner and Ellickson, 1996) and living in an urban setting (McNulty and Bellair, 2003; Roitberg and Menard, 1995) were consistently reported as not being significant risk factors. We should point out that Roitberg and Menard, using data from the first five years (1976-1980) of the National Youth Survey of 1,725 Americans who were 11 to17 years old in 1976, reported that although the influence of socioeconomic status (SES) was significant in the first year of observation, the influence of SES was not significant in the subsequent three years of observation. Even for the first year, after adjusting for multiple comparisons, the influence of SES was not statistically significant. The effects of White ethnicity, alcohol use, illicit drug use, occupational strain, unstable family financial base, and low parental education were inconclusive. The evidence for the remaining 38 of 48 (79 percent) factors was derived from only one cohort study, and thus was considered inadequate as a basis for drawing conclusions.

Among boys in the general population, anger (Felson, 1992; Foshee, Linder, 2001), cigarette smoking (Dornbusch, Lin, 1999; Ellickson, Tucker, 2001) and non-violent delinquency (Becker and McCloskey, 2002; Saner and Ellickson, 1996) were consistently reported as significant risk factors for violence. Low socio-economic status (Brezina, 1999; Saner and Ellickson, 1996) was consistently reported as non-significant. Findings were mixed for the seven remaining risk factors with two or more cohort studies, including age, depression, physical aggression, illicit drug use, non-intact family structure, low parental education, and physical abuse by caretakers. Evidence for the remaining 47 of 58 (81 percent) factors were considered inadequate for assessment as they were investigated in one cohort study only.

For girls in the general population, non-violent delinquency (Becker and McCloskey, 2002; Herrera and McCloskey, 2003; Saner and Ellickson, 1996) was consistently reported as a significant risk factor. Illicit drug use (Dornbusch, Lin, 1999; Saner and Ellickson, 1996) and low parental education (Dornbusch, Lin, 1999; Saner and Ellickson, 1996) were consistently reported as non-significant. Age, cigarette smoking, and non-intact family structure showed mixed effects, and the remaining 44 of 50 (88 percent) factors did not have adequate evidence for assessment.

For at-risk youth (Table 14), male gender (in four of five cohort studies) was consistently reported to be a significant risk factor for violence (Foshee, Bauman, 2000; Herrenkohl, Guo, 2001; McCloskey and Lichter, 2003; Rivera and Widom, 1990). One cohort study found that male gender was a significant risk factor for peer aggression and dating aggression but not for aggression toward parents (McCloskey and Lichter, 2003). Low SES was consistently reported as a non-significant risk factor (Herrenkohl, Egolf, 1997; Herrenkohl, Guo, 2001; Herrera and McCloskey, 2001). However, it should be noted that Herrenkohl and colleagues reported a significant influence of SES in bivariate analysis using data from the Lehigh longitudinal study in 1976 and data from the Seattle Social Development Project in 2001, but the influence of SES was not statistically significant after controlling for the influence of other factors in multivariate analysis. Findings on age, depression, empathy, antisocial behavior, individual involvement in pro-social activities, family's pro-violence attitude, parental violence, deviant peers, and the community's low neighborhood attachment were mixed. Finally, evidence for the remaining 41 of 52 (79 percent) risk factors was inadequate for assessment. One cohort study (Herrera and McCloskey, 2001) found increasing age as a significant risk factor, while two other cohort studies (Herrenkohl, Egolf, 1997; Rivera and Widom, 1990) found age to be a non-significant risk factor.

Among high-risk males, Latino ethnicity and repeated physical aggression (Loeber, Wei, 1999; Loeber, Wung, 1993) were consistently reported as significant risk factors. Impulsivity/attention deficit/hyperactivity disorders were reported as non-significant risk factors in two studies (Becker and McCloskey, 2002; Beyers, Loeber, 2001). Findings regarding an association with age, African-American race, positive attitude toward problem behavior, lack of guilt, having previously engaged in sexual intercourse, weapon carrying, violent behavior, poor academic performance, parental supervision or monitoring, and poor familial communication patterns were all found to be inconclusive. Evidence for the remaining 45 of 58 (78 percent) factors were judged inadequate for assessment, while findings for age were found to be mixed, with two cohort studies reporting it as a significant risk factor (Becker and McCloskey, 2002; Zhang, Loeber, 1997) and one study reporting it as a non-significant finding (Beyers, Loeber, 2001).

Among high-risk females, no factors were consistently reported as significant. Findings for 2 of the 32 risk or protective factors were mixed, and the evidence for the remaining 30 (94 percent) was judged inadequate for assessment.

In summary, although many risk factors were studied in the 23 prospective cohorts reviewed, 58 percent (87 of 151) of the risk factors were examined within only a single cohort study; 34 percent (52 of 151) of the risk factors had mixed findings; and only 8 percent (12 of 151) of the risk factors were consistently reported to be significantly associated with youth violence. Further, those factors that were consistently reported as significant or non-significant in this report were considered without regard to the type of violent outcome, the age at enrollment in the cohort, the type of at-risk population, and the type of analysis. Thus, additional research is needed to assess whether the associations are affected by these factors. Although we considered using meta-analysis techniques to pool findings, we found that the published data were too inconsistent and/or inadequate to allow the use of this technique.

## Key Question #2: What are the patterns of co-occurrence of these factors?

While Key Question #1 was intended to identify independent risk factors that have a high likelihood of leading to youth violence, Key Question #2 was intended to identify clusters of risk factors that may lead to youth violence. The analytic approach to the two key questions is different. Very frequently, a factor that is found to be statistically significant in a univariate or bivariate analysis becomes non-significant after adjusting for other factors in the model. For example, low SES or low family income was reported to be a significant risk factor associated with youth violence in bivariate analysis. The association disappeared (became non-significant) after controlling for the effect of other risk factors in the multivariate model. (Roitberg and Menard, 1995; Saner and Ellickson, 1996; Herrenkohl, Egolf, 1997; Brezina, 1999; Herrenkohl, Guo, 2001; Herrera and McCloskey, 2001) In contrast, Key Question #2 purports to identify clusters of risk factors that occur simultaneously (co-occur) and appear to predispose to youth violence. Unlike the independent factors identified in Key Question #1, the factors in a cluster are likely to be highly correlated and if we subject them to adjustment in multivariate analysis, many will likely become non-significant. Therefore, analytically, while we are looking for independent risk or protective factors in Key Question #1, we are looking for dependent risk or protective factors that occur simultaneously in Key Question #2.

Operationally, we defined co-occurrence as the simultaneous presence of two or more risk or protective factors that predict violence in an individual. Of the 23 longitudinal prospective cohort studies included in our assessment, only five articles from four cohort studies (Beyers, Loeber, 2001; Borowsky, Ireland, 2002; Dornbusch, Lin, 1999; Herrenkohl, Maguin, 2000; Piquero and Tibbetts, 1999) examined different types of co-occurrence of risk- or protective factors..

Using data collected from the National Longitudinal Study of Adolescent Health (Add Health), Dornbusch and colleagues (Dornbusch, Lin, 1999) examined the relationship between young people's use of drugs and involvement in violence and found polydrug use was significantly and positively associated with increased involvement in violence among both boys and girls. This same association was not found between use of a single illicit drug and violence. Also using Add Health data, Borowsky and colleagues (Borowsky, Ireland, 2002) reported the protective nature of three factors, including parent-family connectedness, school connectedness/parental presence, and grade point average; all three were found to be significantly and negatively associated with violence among both males and females. As part of the Seattle Social Development cohort study, Herrenkohl and colleagues (Herrenkohl, Egolf, 1997) reported that youth exposed to multiple risk factors were significantly more likely than non-exposed youth to engage in violence. However, in this study, only the number of risk factors and not the type of factors that co-occurred were reported. In a study that focused on repeated incidence of youth violence among high risk males recruited for the Pittsburgh Youth Study, Beyer and colleagues (Beyers, Loeber, 2001) reported that two combinations of risk factors were significantly associated with repeated violence: 1) low SES neighborhood, lack of guilt, early sexual activity, carrying hidden weapons, and poor communication at home, and 2) high SES neighborhood and physical aggression on the part of the youth. Importantly, whereas SES was consistently not reported as a significant “independent” risk factor in Key Question #1, SES was a significant risk factor when it co-occurred with other risk factors as determined in our analysis for Key Question #2. Data from the nationwide Collaborative Perinatal Project, which followed a cohort of African-American children from birth, Piquero and Tibbetts (Piquero and Tibbetts, 1999) reported that pre/perinatal disturbances — when combined with a disadvantaged familial environment at age seven years — were associated with increased risk for criminal offense during early adulthood among a high-risk, inner-city sample from Philadelphia.

Viewing the findings for both Key Questions #1 and #2, it is evident that both the dependent and independent nature of the risk or protective factors must be properly assessed and clearly differentiated. Until this is done, controversies regarding the significance or non-significance of risk or protective factors will persist.

### Study Quality For Studies For Key Questions #1 and #2

Because all the prospective longitudinal cohort studies included in our review satisfied four of the seven OMAR criteria for study quality in the same ways, we used the three remaining criteria to evaluate the quality of articles addressing risk and protective factors associated with youth violence. The criteria that were the same for all studies included: criterion 1, baseline comparability of groups; criterion 2, use of concurrent controls; criterion 3, equal application of instruments to all groups; and criterion 4, consideration of important outcomes. The three remaining criteria that we used to evaluate the quality of the individual articles are: the follow-up or retention rate (80 percent or greater), validity and reliability of instruments used for assessments, and appropriate control of confounders. Table 15 summarizes our evaluation of these three criteria for the 35 published articles. Because one article (Loeber, Wei, 1999) included three cohort studies, the total of cohorts-articles in Table 15 is 37. We used the cohort-article as the unit of evaluation of study quality, because the evaluation of study quality was based on the information provided in the article and the individual articles might report on different outcomes and different time periods and might use different analytic methods.

Table 15 Quality of the prospective cohort studies for Key Questions #1 and #2

Cohort ID # | Prospective cohort name | Initial cohort size | Study quality criteria | | | Supplemental information
| | | Retention rate >=80%? | Validated instrument? | Appropriate control of confounding factors?^a^ | % (#) participated | % (#) retained | % (#) analyzed | % of initial cohort analyzed
1 | Lehigh Longitudinal Study | 457 | No | Yes | Yes (M) | 100% (457)^b^ | 51–69% (235–317) | 100%^c^ (235–317) | 51–69%
2 | Mother-Child Pair Study | 363 | Yes | Yes | Yes (P) | 100% (363)^b^ | 82% (299) | 96% (287) | 79%
| | 363 | Yes | Yes | Yes (M) | 100% (363)^b^ | 82% (296) | 90–100% (267–295) | 74–81%
| | 179 | No | Yes | Yes (M) | 100% (179)^b^ | 79% (141) | 100% (141)^c^ | 79%
3 | Seattle Social Development Project | 1053 | Yes | Yes | Yes (M) | 77% (808) | 89% (720) | 100% (720)^c^ | 68%
| | 1053 | Yes | Yes^f^ | Yes (P) | 77% (808) | 94% (757) | 107% (807)^d^ | 77%
| | 1053 | Yes | Yes^f^ | Yes (M) | 77% (808) | 94% (757) | 107% (808)^d^ | 77%
| | 200^e^ | Yes | Yes^f^ | Yes (M) | 77% (154) | 94% (144)^e^ | 107% (154)^d^ | 77%
4 | National Youth Survey | 2363^e^ | Yes | Yes | Yes (M) | 73% (1725) | 87% (1494) | 100% (1494)^c^ | 63%
5 | Rand Adolescent Panel Study | 6527^f^ | No | Yes | Yes (M) | 100% (6527)^b^ | 70% (4586) | 100% (4586)^d^ | 70%
| | 6527 | No | Yes^f^ | Yes (M) | 100% (6527)^b^ | 66% (4327) | 100% (4327)^d^ | 66%
| | 6527 | No | Yes^f^ | Yes (M) | 97% (6338) | 67% (4265) | 100% (4265)^d^ | 65%
6 | National Longitudinal Study of Adolescent Health (ADD Health) | 27012^f^ | No | Yes^f^ | Yes (M) | 77% (20745)^f^ | 65% (13568) | 68% (9293) | 34%
| | 27012^e^ | No | Yes | Yes (M) | 77% (20745) | 71% (14738) | 80% (11781)^d^ | 44%
7 | Widom National Institute of Justice Study | 1152^g^ | No | Yes | Yes (M) | 100% (1152) | 79% (908) | 100% (908)^c^ | 79%
8 | Safe Date Program | 1390^e^ | Yes | Yes | Yes (M) | 81% (1126)^e^ | 90% (1013) | 92% (931) | 67%
9 | New York Dating Violence Prevention Program | 206^h^ | Yes | Yes | Yes (M) | 100% (206)^h^ | 100% (206)^h^ | 100% (206)^h^ | NG^h^
10 | Offspring of subjects from the Houston Independent School District Study | 6359 | No | Unsure | Yes (M) | 93% (5887) | 38% (2222) | 96% (2138)^d^ | 34%
11 | National Education Longitudinal Survey | 25000^e^ | No | Unsure | Yes (M) | 100% (25000)^b^ | 66% (16489) | 87% (14358) | 57%
12 | Project Northland | 1266 | Yes | Unsure | Yes (M) | 100% (1266)^b^ | 86%1088 | 86% (937) | 74%
13 | Collaborative Perinatal Project | 2958 | No | Unsure | Yes (M) | 100% (2958) | 33% (987) | 88% (867) | 29%
14 | Durham Longitudinal Study | 622^i^ | No | Yes | Yes (M) | 100% (622)^b^ | 73% (454) | 72% (327) | 53%
15 | Pittsburgh Youth Study^g^ | 597^f^ | Yes | Yes^f^ | Yes (P) | 85% (506) | 86% (435) | 100% (435)^c^ | 73%
| | 1517^h^ | Yes | Yes | Yes (P) | 100% (1517)^h^ | 100% (1517)^h^ | 100% (1517)^h^ | NG^h^
| | 597^e^ | No | Yes | Yes (P) | 85% (506) | 72% (365) | 100% (365)^c^ | 61%
| | 603^e^ | Yes | Yes | Yes (M) | 84% (506) | 83% (420) | 100% (420)^c^ | 70%
| | 603^e^ | Yes | Yes^f^ | Yes (P) | 84% (506)^f^ | 100% (506)^h^ | 100% (506)^h^ | NG^h^
| | 588^e^ | Yes | Yes^f^ | No | 86% (506) | 100% (506) | 93% (470) | 80%
16 | South Florida Longitudinal Study | 9763 | No | Yes | No^k^ | 69% (6760) | 59% (3955) | 82% (3228) | 33%
17 | Denver Youth Survey^j^ | 1527 | Yes | Yes | Yes (P) | 30% (464) | 80% (373) | 100% (373)^c^ | 24%
18 | Rochester Youth Development Study^j^ | 729^b^ | No | Yes | Yes (P) | 100% (729)^b^ | 77% (562) | 100% (562)^c^ | 77%
19 | Buffalo Longitudinal Study of Young Men | 933^e^ | Yes | Yes | Yes (M) | 67% (625) | 95% (596) | 95% (568) | 61%
20 | Youth in Transition | 2213^f^ | Yes | Unsure | Yes (M) | 100% (2213)^b^ | 85% (1886) | 100% (1886)^c^ | 85%
| | 2213 | Yes | Unsure | Yes (P) | 100% (2213)^b^ | 85% (1886) | 81% (1519) | 69%
21 | Oregon Youth Study | 277 | Yes | Yes | Yes (M) | 74% (206) | 95% (195) | 100% (195)^c^ | 70%
22 | White Male Study | 254^e^ | No | Yes | No | 50% (127) | 79% (100) | 64–81% (64–81) | 25–32%
23 | Iowa Family Distress and Coping Study | 263^e^ | No | Yes | Yes (P) | 78% (205) | 79.5% (163) | 69% (113) | 43%

a M=Multivariate analysis or modeling; P=Path analysis or structural equation modeling.

b Initial cohort size or participation rate not given. Thus initial cohort size was assumed to be the same as the number of participants.

c Sample size in analysis assumed the same as sample size retained.

d Missing data estimation techniques or sample weights were used to minimize attrition bias.

e Estimated from information given in article.

f Information obtained from another article that published finding from the same cohort study.

g Information obtained from an additional reference (Widom, 1989) provided by one of the TEG members.

h This article did not provide number or percent for participation, retention, or analysis.

i Stratified random sample from 1749 students.

j The numbers provided here were based primarily on article (Loeber, Wei, 1999) where all three cohort studies were described. Only the number of subjects at the beginning of the studies and the number of participants with complete data were provided. The numbers used in the analysis in the Tables did not match the numbers of subjects with complete data.

k The findings used in this assessment had not been adjusted although multivariate techniques have been used to study other outcomes.

Three of the 37 cohort-articles (O'Leary and Slep, 2003; Stouthamer-Loeber, Loeber, 2001; Zhang, Loeber, 1997) did not provide information on retention rate. Of the articles that documented retention information, 18 (53 percent) reported a retention rate of 80 percent or higher. Because of the lack of information in the articles, we were unsure of the validity or reliability of the instruments used in assessments in six (16 percent) of the cohort-articles (Brezina, 1999; Felson, 1992; Kaplan, Tolle, 2001; Komro, Williams, 1999; McNulty and Bellair, 2003; Piquero and Tibbetts, 1999). Only three articles (8 percent) (Halpern, Udry, 1993; Kingery, Biafora, 1996; Stouthamer-Loeber and Loeber, 2002) did not control for confounding factors in the findings used in our assessment; 24 (65 percent) reported adjusted findings using multivariate techniques; and 10 (27 percent) adjusted for temporal relationship using path analysis or structural equation modeling.

Taking all three criteria into consideration, of the 37 cohort-articles, 16 (43 percent) fulfilled all the criteria and 18 (49 percent) did not fulfill one or more criteria. The three remaining cohort-articles (8 percent) fulfilled two of the three criteria with fulfillment of the third criterion being questionable.

While evaluating the retention (or follow-up) rate, we found inconsistencies not only in its derivation, but also in its adequacy as a measure of sample biases. In general, the sample data on which findings were based were subject to three types of biases: non-participation, loss -to- follow-up (addressed by retention rate), and missing data elements. Therefore, we further assessed quality as it relates to potential sample biases. In Table 15, we examine a) the number of participants and the percent of the eligible subjects who participated; b) the number and percent of participants retained in the study; c) the number and percent of participants whose data were analyzed, the denominator of which was the number of participants retained at the last follow-up; and d) the percent of participants in the initial cohort that were analyzed. The last indicator represents the net sample percent used in the analysis. We excluded three cohort-articles that did not provide adequate information (O'Leary and Slep, 2003; Stouthamer-Loeber, Loeber, 2001; Zhang, Loeber, 1997) in the comparison. If the retention rate was used as the criterion, 18 of 34 cohort-articles (53 percent) reported a retention rate of 80 percent or higher. However, if the percent of original sample used in the analysis was used as the criterion, only three of 34 articles (9 percent) had a net sample percent of 80 percent or higher.

It is also interesting to compare the reporting of retention rates in multiple articles that used data from the same cohort study. Six cohort studies had findings published in more than one article. The articles based on the RAND Adolescent Panel Study (Ellickson, Tucker, 2001; Ellickson, Tucker, 2003; Saner and Ellickson, 1996) consistently reported retention rates under 80 percent. The articles based on the Add Health Survey (Borowsky, Ireland, 2002; Dornbusch, Lin, 1999) also consistently reported retention rates under 80 percent. The articles based on the Seattle Social Development Project (Herrenkohl, Guo, 2001; Herrenkohl, Hill, 2003; Herrenkohl, Maguin, 2000;Huang, Kosterman, 2001) consistently published retention rates over 80 percent. However, articles based on the Mother-Child Pair Study (Becker and McCloskey, 2002; Herrera and McCloskey, 2003; McCloskey and Lichter, 2003); the Pittsburgh Youth Study (Beyers, Loeber, 2001; Loeber, Wei, 1999; Loeber, Wung, 1993; Stouthamer-Loeber and Loeber, 2002; Stouthamer-Loeber, Loeber, 2001; Zhang, Loeber, 1997); and the Michigan's Youth in Transition Project (Brezina, 1999; Felson, 1992) reported inconsistent retention rates.

We believe that the participation rate, follow-up or retention rate, and complete data rate should be considered when assessing the possibility of bias in the study sample, particularly for outcomes such as violence. The risk factors that are likely to contribute to violent outcomes are also likely to contribute to non-participation, loss-to-follow-up, or missing data. It is important to point out that researchers have made considerable efforts to correct attrition or sample biases. Missing data estimation techniques or sample weights have been used in eight articles (Borowsky, Ireland, 2002; Ellickson, Tucker, 2001; Ellickson, Tucker, 2003; Herrenkohl, Guo, 2001; Herrenkohl, Hill, 2003;Huang, Kosterman, 2001; Kaplan, Tolle, 2001; Saner and Ellickson, 1996) to minimize sample size biases.

### Sensitivity Analysis

To gain a better understanding of the strength of the evidence on reported risk- or protective factors, we conducted two sensitivity analyses to examine the risk or protective factors consistently reported as being associated or not associated with youth violence perpetration. First we reanalyzed the data after excluding the studies with sample size below the thresholds set at 1100 for the general population and 500 for the at-risk population. As a result, 20 articles from 13 cohort studies (out of an original 35 articles from 23 cohort studies) were included in the first sensitivity analysis. In the second sensitivity analysis, we excluded the studies that did not meet all the OMAR study quality criteria. Thus, 16 articles from nine cohort studies were included in the second sensitivity analysis. We did not perform a sensitivity analysis using articles that had both adequate sample size and good study quality because only four articles from three cohort studies satisfied both criteria, and no significant findings were reported based on these four articles.

The findings of the two sensitivity analyses are reported in Table 16. For each factor, we use a string of three symbols to designate the significance or non-significance of the association. The first symbol in the string represents the finding when all studies are included, the second symbol in the string represents the finding when only studies with adequate sample size are included, and the third symbol represents the finding when only studies with good study quality are included. A “+” symbol indicates a consistent finding of an association between the risk factor and youth violence perpetration, and a “o” symbol indicates no consistent finding of no association between the risk factor and youth violence perpetration.

Table 16 Assessment of the strength of evidence for Key Questions #1 and #2

Study Population | | Factor Domain | Factors consistently reported as being associated with violence^a^ | All studies | Only studies with adequate sample size | Only studies with good study quality
Type | Gender | | | 23 cohort studies, 35 articles ^b^ | 13 cohort studies, 20 articles ^b^ | 9 cohort studies, 16 articles ^b^
(A) Factors consistently reported as being associated with violence
All | Both | Individual | + + + Male gender | (8) (2) | (5) (0) | (3) (1)
| | | o + o African-American | (5) (3) | (3) (1) | (2) (2)
| | | + o o Antisocial behavior | (3) (1) | (1) (1) | (2) (2)
| | | + o o Alcohol use | (3) (1) | (2) (1) | (0) (0)
| | | + + o Alcohol/drug use | (3) (1) | (2) (0) | (1) (1)
| | | + + o Selling drugs | (2) (0) | (2) (0) | (1) (0)
| | | o + o Weapon carrying | (3) (2) | (2) (0) | (1) (2)
| | | o + o Violent behavior | (2) (1) | (2) (0) | (1) (1)
| | | + o o Non-violent delinquency | (2) (0) | (1) (0) | (1) (0)
| | | o + o Poor academic performance | (3) (2) | (3) (1) | (1) (1)
| | | + o o Repeated physical aggression | (2) (0) | (1) (0) | (1) (0)
| | Home/Family | + + o Parental attachment | (2) (0) | (2) (0) | (1) (0)
| | Peer | o + o Delinquent or violent peers | (3) (2) | (2) (0) | (3) (2)
General population | Both | Individual | + + o Male gender | (3) (1) | (2) (0) | (1) (0)
| | | + o + Alcohol/drug use | (2) (0) | (1) (0) | (0) (0)
| Male | Individual | + o o Anger | (2) (0) | (1) (0) | (1) (0)
| | | + + o Cigarette use/smoking | (2) (0) | (2) (0) | (0) (0)
| | | + o o Non-violent delinquency | (2) (0) | (1) (0) | (0) (0)
| Female | Individual | + o o Non-violent delinquency | 2) (0) | (1) (0) | (0) (0)
At-risk population | Both | Individual | + + o Male gender | (4) (1) | (2) (0) | (2) (1)
| Male | Individual | o + o African-American | (3) (2) | (2) (0) | (2) (2)
| | | + + o Latino | (3) (1) | (3) (0) | (1) (2)
| | | + + o Repeated physical aggression | (2) (0) | (2) (0) | (1) (0)
| Female | Individual | + o o Non-violent delinquency | (2) (0) | (1) (0) | (0) (0)

a ‘+’ denotes consistent association; ‘o’ denotes no consistent association; a string of ‘+’ and ‘o’ denotes findings reported in the three groups of studies, the first being all studies considered, the second being only studies with adequate sample size considered; and the third being only studies with good study quality.

b The first number in parenthesis is the number of cohorts reported a statistically significant association (p<0.05) in the article. The second number in parenthesis is the number of cohorts that reported no statistically significant association (p≥0.05) in the article.

Table 16 Assessment of the strength of evidence for Key Questions #1 and #2

Study Population | | Factor Domain | Factors consistently reported as being NOT associated with violence^a^ | All studies | Only studies with adequate sample size | Only studies with good study quality
Type | Gender | | 23 cohort studies, 35 articles^b^ | 13 cohort studies, 20 articles ^b^ | 9 cohort studies, 16 articles ^b^ | Only studies with good study quality^b^
(B) Factors consistently reported as being NOT associated with violence
All | Both | Individual | + + o Age | (2) (7) | (1) (3) | (2) (4)
| | | + o o Asian Pacific Islander | (0) (2) | (2) (2) | (0) (0)
| | | + + o Other ethnicity | (0) (2) | (0) (2) | (0) (1)
| | Home/Family | + + + Low socioeconomic status | (0) (7) | (0) (4) | (0) (3)
| | | + o o Low parental education | (1) (3) | (1) (2) | (0) (1)
| | | + o o Parental violence | (1) (3) | (0) (1) | (1) (2)
| | | o o + Family connectedness | (1) (2) | (0) (2) | (0) (1)
| | Community | + + o Urban residence | (0) (2) | (0) (2) | (0) (1)
General population | Both | Home/Family | + + o Low socioeconomic status | (0) (2) | (0) (2) | (0) (1)
| | Community | + + o Urban residence | (0) (2) | (0) (2) | (0) (1)
| Male | Home/Family | + + o Low socioeconomic status | (0) (2) | (0) (2) | (0) (0)
| | | o + o Low parental education | (1) (2) | (0) (2) | (0) (1)
| Female | Individual | + + o Illicit drug use | (0) (2) | (0) (2) | (0) (0)
| | Home/Family | + + o Low parental education | (0) (3) | (0) (2) | (0) (1)
At-risk population | Both | Home/Family | + o o Low socioeconomic status | (0) (3) | (0) (0) | (0) (0)
| Male | Individual | + o + Impulsive-attention deficit | (0) (2) | (0) (0) | (0) (2)

a ‘+’ denotes consistent association; ‘o’ denotes no consistent association; a string of ‘+’ and ‘o’ denotes findings reported in the three groups of studies, the first being all studies considered, the second being only studies with adequate sample size considered; and the third being only studies with good study quality.

b The first number in parenthesis is the number of cohorts reported a statistically significant association (p<0.05) in the article. The second number in parenthesis is the number of cohorts that reported no statistically significant association (p≥0.05) in the article.

Factors consistently reported as being associated with violence. Male gender was the only factor that was consistently reported as being associated with violence in all three analyses. “Alcohol or drug use” and “selling drugs” in the individual domain and “low parental attachment” in the home/family domain were consistently reported as being associated with violence in two of the three analyses. Nine factors were reported as being associated with violence in one of the three analyses (Table 16).

When the six individual study populations were considered, no single factor was consistently reported as being associated with violence in all three analyses. Male gender (in both the general and at-risk populations); alcohol or drug use in the general population; cigarette use or smoking in the general male population; the Latino race in the at-risk male population; and repeated physical aggression in the at-risk male population were consistently reported to be associated with violence in two of the three analyses. Five factors were consistently reported to be associated with violence in one of the three analyses (Table 16).

Factors consistently reported not to be associated with violence. The identification of particular factors in Table 16 as consistently not being associated with violence must be interpreted with caution. Some of these factors were significant risk or protective factors in univariate or bivariate analysis but were non-significant after adjustment for other risk factors in the multivariate model. While these factors were not independent risk factors, they could be risk factors when considered along with other risk factors as we have discussed in the previous section. Low family SES was consistently reported as not being an independent risk factor for violence. Age, ethnicity other than those listed, urban residence, illicit drug use in the general female population, and impulsive-attention deficit were not associated with violence in two of the three analyses.

Summary. We have examined the adequacy, quality, and consistency of the studies and reported the sensitivity of the findings. When sample size and study quality were considered, only male gender was consistently reported as being associated with youth violence perpetration, and low family SES was consistently reported not to be associated with youth violence as an independent predictor. Reported significance or non-significance showed little consistency for all other risk factors.

## Key Question #3: What evidence exists on the safety and effectiveness of interventions for violence?

A total of 32 articles were selected to address Key Questions #3, #4, and #5, the questions that address safety and effectiveness of interventions. Table 17 provides the numbers of articles by intervention level (primary, secondary, and tertiary prevention, according to the definitions provided in Chapter 2) and by study design. Two articles reported findings for primary and secondary prevention interventions in the same article. Thus, a total of 34 intervention studies are summarized in this table. Table 18 lists the unit of randomization for randomized controlled studies (RCTs) and the name of the intervention. We provide a description of each intervention program and its findings for the five primary prevention interventions conducted by RCT in Table 19, for the 10 primary prevention interventions conducted using other study designs in Table 20, for the secondary prevention interventions conducted by RCT in Table 21, for the four secondary prevention interventions conducted using other study designs in Table 22, for the two tertiary prevention interventions evaluated by RCT in Table 23, and for the five tertiary interventions evaluated using other types of study designs in Table 24.

Table 17 Intervention articles by type and study design

Intervention level ^a^ | Study design | Number of article ^b^ | Number of intervention
Primary | Total | 16 | 15
(Interventions that are universal, intended to prevent the onset of violence and related risk factors) | Randomized controlled trial | 6 | 5
| Non-randomized controlled trial | 5 | 5
| Prospective comparative cohort | 0 | 0
| Cross-sectional comparative cohort | 2 | 2
| Single cohort pre and post design | 1 | 1
| Incomplete randomized controlled trial | 1 | 1
| Partially randomized with cross-over design | 1 | 1
Secondary | Total | 11 | 10
(Interventions that are implemented on a selected scale for children/youth at enhanced risk for youth violence, prevent onset and reduce the risk of violence) | Randomized controlled trial | 7 | 6
| Non-randomized controlled trial | 2 | 2
| Prospective comparative cohort | 0 | 0
| Cross-sectional comparative cohort | 0 | 0
| Single cohort pre and post trial | 1 | 1
| Non-randomized pre and post trial | 1 | 1
Tertiary | Total | 7 | 7
(Interventions that are targeted to youth who have already demonstrated violent or seriously delinquent behavior) | Randomized controlled trial | 2 | 2
| Non-randomized controlled trial | 2 | 2
| Prospective comparative cohort | 0 | 0
| Cross-sectional comparative cohort | 0 | 0
| Single cohort pre and post design | 1 | 1
| Retrospective single group time series | 1 | 1
| Pre and post trial with comparison group | 1 | 1
Total | | 34 | 32

a Source: Definitions from the Surgeon General's Report on Youth Violence.

b Two articles involved both primary and secondary interventions. Thus the total number of articles is 34.

Table 18 Intervention studies categorized by level and study design

Level | Study type | Unit of randomization | Intervention | Article ID#
Primary | Randomized controlled trial (RCT) | School | Safe Dates Program | 2260, 2261
| | School | Drug Abuse Resistance Education (DARE and DARE PLUS) | 9
| | School | Student for Peace (Multi-component violence-prevention program) | 739
| | Team of students | Students Management Anger and Resolution Together (SMART Talk) | 5246
| | Homeroom | Responding in Peaceful and Positive Ways - 7th grade (RIPP-7) | 5871
| Non-randomized controlled trial (NRCT) | | Improving Social Awareness-Social Problem Solving Project (ISA-SPS) | 5796
| | | Teacher training, parent education, and social competence training | 117
| | | Chicago Child-Parent Center (CPC) Program | 3965
| | | Peaceful Conflict and Violence Prevention Curriculum (13 modules) | 1579
| | | Reach for Health Community Youth Service program | 3680
| Cross-sectional study | | Georgia's legislative waiver in deterring juvenile crime | 7615
| | | School-based metal detector program | 4048
| Single cohort pre and post design | | Violence prevention program and conflict resolution curriculum | 393
| Incomplete randomized controlled trial | | All Stars character education and problem behavior prevention program | 2588
| Partially randomized with cross-over | | A traditional martial arts training program (Koga Ha Kosho Shorei Ryu Kempo) | 4962
Secondary | Randomized controlled trial (RCT) | School | Safe Dates Program | 2260, 2261
| | School | Project Towards No Drug Abuse (TND) | 4315
| | Family | Moving to Opportunity (MTO) demonstration project | 10598
| | Youth bureau | Early community-based intervention for prevention of substance abuse and delinquent behavior | 6221
| | Subject | Triple modality social learning program | 5995
| | Subject | Childhaven's therapeutic child-care program (formerly Seattle Day Nursery) | 7158
| Non-randomized controlled trial | | Positive Adolescents Choices Training (PACT) | 2563
| | | 5 weeks treatment of SSRI (selective serotonin reuptake inhibitors) | 1308
| Single cohort pre and post design | | Conflict resolution model of family-systems intervention for individual parent-child dyads | 5758
| Non-randomized pre-and post- trial | | Alternative to Suspension for Violent Behavior (ASVB) | 5301
Tertiary | Randomized controlled trial (RCT) | Subject | Turning Point: Rethinking Violence (TPRV) | 40
| | Subject | Multi-systemic therapy (MST) | 2644
| Non-randomized controlled trial | | Project Back-on-Track (an after school diversion program) | 692
| | | A multimodal treatment approach with two orientations | 10786
| Single cohort pre and post design | | Outpatient Behavioral Management of Aggressiveness in Adolescents | 7973
| Pre and post trial with comparison group | | Multi-systemic Therapy (MST) vs. Individual therapy | 1729
| Retrospective single group time series | | Stout Cottage Serious Sex Offenders Program (SSOP) | 6187

Table 19 Program characteristics and findings for [underlined: primary] interventions evaluated with [underlined: randomized controlled trials]

Program name and setting | Study population | | Description of program | Findings
(A) Primary intervention reporting effectiveness, randomized controlled trial
RIPP- 7th grade (RIPP-7) (#5871) | 7th graders | | • 12 weekly session skills building program, | Violent behavior per 100 students at post-test and 1-year follow-up,
• School setting | M | 47% | • focused on conflict resolution, | | [underlined: Adjusted rate] | | [underlined: Rate ratio] | p
| F | 53% | • implemented by trained preventionists, | | Treated (n=239) | Control (n=237) | Control/treated
| AA | 97% | • use of experiential activities | • Post-test: | 2.9 | 3.7 | 1.3 (0.4, 4.0) | ns
| O | 3% | | • 1-year: | 11.2 | 23.1 | 2.1 (1.1, 3.7) | <0.05
(B) Primary intervention not reporting effectiveness, randomized controlled trial
Safe Dates Program (#2260 & #2261) | 8th and 9th graders reported not a victim or perpetrator of dating violence | | This program consists of school and community activities. Key components: | Mean score, treated (n=7 schools) vs control (n=7 schools)
• School setting | M | 49% | • 10 45- minute sessions conducted by teachers focused on changing norms associated with partner violence, decreasing gender stereotyping, and improving conflict management skills, | • Sexual violence perpetration at 1 month: 0.01 vs 0.04 , p=ns
• community setting | F | 51% | • a theater production performed by peers, | • Violence in current relationship at 1 month: 0.01 vs 0.03, p=ns
| W | 77% | • a poster contest for dating violence prevention | Mean score, treated (n=7 schools) vs control (n=7 schools)
| AA | 19% | • 20 workshops for community service providers | • Sexual violence perpetration at 1 year: 0.05 vs 0.07 , p=ns
| O | 4% | Control group had the theater and community activities. | • Violence in current relationship at 1 year: 0.05 vs 0.08, p=ns
| | | | (No measures of variation reported)
DARE (#0009) | 7th and 8th graders | | DARE | Growth rate±SE of self-reported violent behavior derive from 18-month follow-up.
• School setting | M | 52% | • 10 week skill-building curriculum taught by police officers | Male, treated (DARE: n=1269; DARE plus: n=1381) vs control (n=1093):
| F | 48% | DARE PLUS | • DARE: vs control: | | 0.57±0.09 vs 0.54±0.09 , p=0.41
| W | 67% | • 10 week skill-building curriculum taught by police officers | • DARE plus vs control: | | 0.35±0.08 vs 0.54±0.09, p=0.06
| AA | 8% | • 4-week peer- led parent involvement program | Female, treated (DARE: n=1249; DARE plus: n=1254) vs control (n=1015):
| API | 13% | • Youth- led extracurricular activities | • DARE vs control: | | 0.26±0.07 vs 0.30±0.07, p=0.34
| L | 4% | • Neighborhood action teams to address neighborhood and school-wide issues. | • DARE plus vs control: | | 0.23±0.07 vs 0.30±0.07, p=0.24
| O | 9%
SMART Talk (#5246) | 6th – 8th graders | | • computer based multimedia program used independently by students during a single semester | Mean±SD aggressive score over past 30 days measured on 4 aggressive behaviors at 4 months after implementation of intervention.
• School setting | M | 46% | • three major components include anger management, perspective talking, and dispute resolution. | Male, treated (n=145) vs control (n=90): 16.1±6.2 vs 16.9±6.2, p=ns
| F | 54% | • Free access to program during semester | Female, treated (n=176) vs control (n=105): 14.0±5.2 vs 13.9±5.6, p=ns
| W | 84%
| AA | 9%
| O | 7%
Student for Peace (#0739) | 6th graders followed through 7th and 8th grades | | • Formation of a School Health Promotion Council | Adjusted difference between treated (n=929) and control (n=1161) at 1-year follow-up and between treated (n=788) and control (n=975) at 2-year follow-up on frequency (sample sizes not broken down by gender):
• School setting | M | 50% | • Training of peer mediators and peer helpers | Male, 1-year follow-up, difference (95% CI):
• Home setting | F | 50% | • Training of teachers in conflict resolution, | • Fighting: | | -1.2 (-8.5, 6.2) | ns
| W | 8% | • A 3-semester violence-prevention curriculum | • Fighting with injuries: | | -2.7 (-7.0, 1.5) | ns
| AA | 17% | • Monthly newsletters for parents | • Threaten to hurt: | | -8.8 (-18.9, 1.3) | ns
| API | 4% | | Male, 2-year follow-up, difference (95% CI):
| L | 68% | | • Fighting: | | -6.3 (-14.1, 1.6) | ns
| O | 3% | | • Fighting with injuries: | | -6.7 (-11.3, 2.1) | ns
| | | | • Threaten to hurt: | | -0.3 (-10.9, 10.4) | ns
| | | | Female, 1-year follow-up, difference (95% CI):
| | | | • Fighting: | | -2.1 (-8.5, 4.6) | ns
| | | | • Fighting with injuries: | | 0.9 (-3.6, 5.3) | ns
| | | | • Threaten to hurt: | | 1.9 (-5.5, 9.3) | ns
| | | | Female, 2-year follow-up, difference (95% CI):
| | | | • Fighting: | | 0.1 (-6.9, 7.1) | ns
| | | | • Fighting with injuries: | | -0.7 (-5.3, 3.9) | ns
| | | | • Threaten to hurt: | | -0.6 (-7.2, 8.3) | ns

Notes: AA African American, API Asian Pacific Islander, CI Confidence Interval, DARE Drug Abuse Resistance Education, F female, L Latino/Latina, M Male, O Other, RIPP Responding in Peaceful and Positive Ways, SMART Students Management Anger and Resolution Together, W White

Table 20 Program characteristics and findings for[underlined: primary] interventions evaluated with[underlined: other study designs]

Program name and setting | Study design | Study population | | Description of program | Findings
(A) Primary intervention reporting effectiveness, other study design
Seattle Social Development Project Intervention (#0117) | Non-randomized controlled trial | Full: 1 – 6 grades | | • 5 day teacher training on proactive classroom management, interactive teaching, and cooperative learning | Reduction in lifetime violent behavior 6 year after intervention at age 18 years.
• School setting | | Late: 5 – 6 grades | | • 4 hours of student training (grade 6) to recognize and resist social influences to engage in problem behaviors | Early (n=149) vs Control (n=206):
| | M | 51% | • voluntary parent training classes in child behavior management skills | Difference (95% CI): | -11.4 (-21.3 to -0.4), p=0.04
| | F | 49% | | Late (n=243) vs Control (n=206):
| | W | 45% | | Difference (95% CI): | -3.3 (-12.0 to 6.3), p=0.54
| | O | 55%
Chicago Child-Parent Center Program (CPC) (#3965) | Non-randomized controlled trial | Preschool and kindergarten inner city children | | Multi-component on education and family support. | Adjusted mean arrests for violent offenses between ages 10 and 18 years (adjusted for gender, race, risk index, early/late program, and site)
Settings: | | Gender: not specified | | • structured learning activities | •Preschool children, treated (n=837) vs control (n=444)
• Preschools | | AA | 93% | • multifaceted parent program | Mean arrest: | 0.22 vs 0.35, p=0.02
• Kindergarten | | L | 7% | • outreach activities | • School-age children, treated (n=729) vs control (n=552)
• 1st, 2nd, 3rd graders | | | | • ongoing staff development | Mean arrest: | 0.28 vs 0.25, p=0.64
• Neighborhood centers | | | | • health and nutrition services | (No measures of variation reported)
| | | | • comprehensive school-age service
| | | | • year round
| | | | • full day or part day
Reach for Health Community Youth Service (CYS) Program (#3680) | Non-randomized controlled trial | 7th and 8th graders in inner cities | | Curriculum Only: | Regression coefficient (SD) for violent behavior in past three months measured at 6-month follow-up (gender, race, grade, and social desirability are covariates.)
Setting: | | M | 46% | 35-session curriculum over 6 months focused on drug and alcohol use, violence and sex delivered by trained teachers, including 10-session focusing on violence prevention. | Both 7th and 8th graders (n=914):
• School | | F | 54% | Curriculum + CYS: | Curriculum + CYS: | -0.037 (0.028), p=ns
• Community site | | AA | 80% | Curriculum described above plus CYS program where students spend approx 3 hours a week at a community site. | Curriculum Only: | -0.016 (0.068), p=ns
| | L | 15% | | 7th graders (n=469):
| | O | 5% | | Curriculum + CYS: | 0.102 (0.079), p=ns
| | | | | Curriculum Only: | 0.010 (0.083), p=ns
| | | | | 8th graders (445):
| | | | | Curriculum + CYS: | -0.206 (0.096), p<0.05
| | | | | Curriculum Only: | -0.036 (0.113), p=ns
Violence Prevention Curriculum for Adolescents and Conflict Resolution Curriculum for Youth Providers (#0393) | Single group pre and post design | 6th–8th graders | | Two curricula | Frequency of fighting, and frequency of injury in previous 30 days measured at 1 week pre and 1 week post intervention
• School setting | | M | 48% | 1) violence prevention curriculum: | Mean±SD for Violence Prevention n=146), after vs before
| | F | 52% | • 10 50-minute sessions in a classroom | Violence scale: | 0.39±1.28vs 0.82±1.79p=.004
| | W | 10% | • focused on violence and violence prevention. | Frequency of fighting: | 0.51±1.26vs 1.37±1.75p=.001
| | AA | 89% | 2) conflict resolution curriculum: | Fighting resulted in injury: | 0.20±0.78 vs 0.15±0.48 p=.105
| | O | 1% | • 10 50-minute sessions in a classroom | Mean±SDfor Conflict Resolution (n=63), after vs before
| | | | • focused on conflict resolution. | Violence scale: | 0.51±1.38vs 0.73±1.65p=.004
| | | | | Frequency of fighting: | 1.03±1.51vs 1.74±1.99p=.001
| | | | | Fighting resulted in injury: | 0.28±0.63 vs 0.59±1.08 p=.105
(B) Primary intervention not reporting effectiveness, other study design
Improving Social Awareness-Social Problem Solving Project (ISA-SPS) (#5796) | Non-randomized controlled trial | 4th and 5th graders | | • social decision-making, problem-solving and social awareness skills program | Mean score measured 6 years after intervention at 9th–11th grades (n=unknown)
• School setting | | Gender and race/ethnicity not specified | | • 2 year program with 3 phases: readiness, instructional and application | Male, mean score treated vs control:
| | | | | • striking/threatening students | .69 vs .59
| | | | | • attack with intent to injure | .37 vs .46
| | | | | • striking/attacking parents | .15 vs .23
| | | | | Female, mean score treated vs control:
| | | | | • striking/threatening students | .77 vs .76
| | | | | • attack with intent to injure | .68 vs .79
| | | | | • striking/attacking parents | .04 vs .05
| | | | | (No measures of variation reported)
| | | | Notes:
| | | | 1) Although the experimental group was divided into high fidelity and low fidelity. No differences between them were found. Thus we report here the findings of the combined experimental group.
| | | | 2) No sample sizes and no standard errors were provided. Significance of differences could not be determined.
| | | | 3) For males, the discriminant analysis findings could not be used because it included both violent and non-violent outcomes.
| | | | 4) For females, the discriminant function that significantly differentiated the experimental and control students did not include any of the three violent outcomes indicating their insignificant contributions.
Peaceful Conflict and Violence Prevention Curriculum (#1579) | Non-randomized controlled trial | Middle school students living in or around public housing | | • Skill-building curriculum based on Social Cognitive Theory | Use of violence in previous 30 days, assessed on a 5-item scale ranged from 0 to 20, at 2-week pre and 2-week post intervention.
• School setting - health education classes | | M | 49% | • 13-week session, one hour per week | Mean±SD violence score, treated (n=233) vs control (n=330)
| | F | 51% | | • Pre-test | 1.4±2.9 vs 1.1±2.0, p=0.31
| | AA | 89% | | • 2-week post-test | 1.12.2± vs 1.2±2.4, p=0.63
| | O | 11% | | Mean±SD score for fighting requiring medical attention, treated n=233 vs control n=330):
| | | | | • Pre-test | 0.28±0.81 vs 0.14±0.50, p=0.01
| | | | | • 2-week post-test | 0.17±0.57 vs 0.17±0.56, p=0.97
School-based hand-held metal detector program (#4048) | Cross-sectional study | 9th – 12th graders | | • school-based metal detector program | Percent (95% CI) students involved in a physical fight at least once during school-year after intervention
• School setting | | Gender and Ethnicity not specified | | • one school year | Treated (n=243) vs control (n=1156):
| | | | • weekly visit by a team of security officers | Anywhere | 26.2 (14.4, 38.0) vs 24.4 (21.5, 27.3) p=ns
| | | | • students scanned at random | To/From school | 9.4 (6.4, 12.3) vs 9.1 (5.6, 12.6) p=ns
| | | | | Inside school | 7.5 (0.4, 14.5) vs 7.8 (4.9, 10.7) p=ns
Juvenile Justice Reform Act 1994 of Georgia - legislative waiver in deterring juvenile crime (#7615) | Cross-sectional study at 2 time points, one before and one after | Adolescent population in the State of Georgia | | Study the effects of new law on serious juvenile crime. Georgia's Juvenile Justice Reform Act mandated that adolescents 13–17 arrested for murder, voluntary manslaughter, rape, aggravated sexual battery, aggravated child molestation; aggravated sodomy, or firearm robbery, be tried as adult. | Mean arrest rate for aggravated assault, robbery, sex offense, rape, murder (unit not provided)
• State of Georgia | | No breakdown by age, gender or race | | | Mean arrest rate, after vs before(n not given)
| | | | | Aggravated assault | 1726 vs 1833, p=ns
| | | | | Armed robbery | 857 vs 749, p=ns
| | | | | Sex offense | 426 vs 394, p=ns
| | | | | Rape | 118 vs 121, p=ns
| | | | | Murder | 83 vs 82, p=ns
| | | | | Total | 3211 vs 3179, p=ns
| | | | | (No measures of variation reported)
All Stars Character Education and Problem Behavior Prevention Program (#2588) | Incomplete randomized controlled trial | 6th or 7th graders | | Character education and problem behavior prevention program facilitated by trained adult interventionists and teachers in classrooms. | Mean of 10 items on violence towards other persons at post-test and at 1-year follow-up. (Treated n=629; Control n=739; not broken down by race/ethnicity)
• School setting | | M | 45% | • Program includes whole classroom sessions, small-group sessions outside of class, and one- on-one sessions between instructor and student. | African-American, Specialist vs Teacher vs Control
| | F | 55% | • Homework is used to increase interaction between students and parents | Pre-test | 1.41 vs 1.35 vs 1.35, p=ns
| | W | 69% | • Study examines difference in impact by type of instructor | Post-test | 1.38 vs 1.32 vs 1.40, p=ns
| | AA | 25% | • 8-month duration | 1-year follow-up | 1.54 vs 1.27 vs 1.59, p=ns
| | L | 6% | | Latino, Specialist vs Teacher vs Control
| | | | | Pre-test | 1.28 vs 1.24 vs 1.19, p=ns
| | | | | Post-test | 1.34 vs 1.22 vs 1.18, p=ns
| | | | | 1-year followo-up | 2.07 vs 1.22 vs 1.34, p=ns
| | | | | White, Specialist vs Teacher vs Control
| | | | | Pre-test | 1.26 vs 1.28 vs 1.25, p=ns
| | | | | Post-test | 1.31 vs 1.27 vs 1.27, p=ns
| | | | | 1-year follow-up | 1.40 vs 1.42 vs 1.37, p=ns
| | | | | (No measures of variation reported)
A traditional martial arts training program (Koga Ha Kosho Shorei Ryu Kempo) (#4962) | Partially randomized controlled trial with cross-over | 6th and 7th graders | | • a traditional martial arts training program | 9-item violence score, rated by teacher, at 4-month follow-up
• School setting | | M | 100% | • course was taught by a martial arts master | Mean±SD violent score, treated (n=31) vs control (n=17):
| | Race/Ethnicity not specified | | • 30 sessions | 3.20±1.46 vs 3.34±1.05, p=ns
| | | | • 3 times per week
| | | | • 45 minutes each

Table 21 Program characteristics and findings for [underlined: secondary] interventions evaluated by [underlined: randomized controlled trials]

Program name and setting | Study population | | Description of program | Findings
(A) Secondary intervention reporting effectiveness, randomized controlled trial
Moving to Opportunity (MTO) demonstration - A Housing Mobility Experiment with 2 programs (#10598) | Teens in high-poverty neighborhoods who are “at risk” for criminal involvement | | • Housing mobility experiment to study the effects of relocating families from high to low poverty neighborhoods on juvenile crime. | Incidence and prevalence of regression-adjusted violent-crime arrest rates per quarter over an average of 3.7 years post-program (assault, robbery, attempted murder)
• Community setting | M | 47% | • MTO group: experimental families with section 8 housing vouchers that can only be redeemed for housing in census tracts with 1990 poverty rates less than 10% and received housing-search assistance and life-skills counseling. | Incidence per 100 teens
| F | 53% | • Section 8 group: families with section 8 housing vouchers which provide subsidies to lease private-market housing. | MTO(n=148) | Control(n=96) | Diff (SE)
| AA | 97% | • Control group: families on MTO waiting list | 2.5 | 5.7 | -3.2 (1.5) p<0.01
| O | 3% | | Section 8(n=92) | Control (n=96) | Diff (SE)
| | | | 1.9 | 4.3 | -2.4 (1.2) p<0.01
| | | | Prevalence during post-program period in %
| | | | MTO (n=148) | Control (n=96) | Diff (SE)
| | | | 2.4 | 5.0 | -2.6 (1.4) p<0.05
| | | | Section 8 (n=92) | Control (n=96) | Diff (SE)
| | | | 1.9 | 3.9 | -2.0 (1.1) p<0.05
Early community-based intervention for the prevention of substance abuse and other delinquent behavior (#6221) | Inner-city youth at high risk of adopting a deviant lifestyle | | Early intervention and risk reduction program: | 6-month self-report physical violence behavior (physical assault, mugging, robbery with weapon, arson, gang fight, shooting at someone) at 1-year follow-up (Treated: n=235; Control: n=193)
• Community-based “youth bureaus” clinic | M | 59% | • individual counseling | Poisson regression results for violent activity during the preceding 6 months at 1-year follow-up revealed significant treatment effects at p=0.0026.
| F | 41% | • group mentoring (no group counseling) sessions available 4–5 days a week including structured skill building activities, educational and recreational field trips, and holiday celebrations | (No descriptive statistics for this indicator reported)
| W | 3% | • informal parent discussions and parent child social events
| AA | 97% | • 4–5 days per week after school and weekends over about 1 year or more
Childhaven's therapeutic child-care program (formerly Seattle Day Nursery) (#7158) | Abused, neglected, and at risk infants and toddlers (ages 1 month through 5 years of age) and their parents | | Therapeutic childcare program for abused, neglected, and at risk infants and children. | 1. Violent crimes (assault) from juvenile court and school files during 12 years of follow-up
• Child care center | Gender and race: not reported | | Parent program elements include: | 2. Incidence of “fighting” from school files during 12 years of follow-up
| | | • voluntary parent education | Violent crimes, treated (n=21) vs control (n=14)
| | | • counseling | % reported yes | 4% vs 24%, p<0.08
| | | • support groups | Mean violent arrests | 0.04 vs 0.30, p<0.05
| | | • linkage to professional services | Incidence of fighting, treated (n=21) vs control (n=14)
| | | • average length of participation is 23 months (62% parents had major participation; 25% parents had no participation) | % reported yes | 12% vs 36%, p<0.05
| | | | Mean times fighting | 0.2 vs 0.8, p=ns
| | | | (No measures of variation reported)
(B) Secondary intervention not reporting effectiveness, randomized controlled trial
Safe Dates Program (#2260, #2261) | 8th and 9th graders who were perpetrators of violence | | This program consists of school and community activities. Key components: | Mean score at 1 month, treated (n=7 schools) vs control (n=7 schools)
Setting | M | 49% | • 10 45- minute sessions conducted by teachers focused on changing norms associated with partner violence, decreasing gender stereotyping, and improving conflict management skills, | • Sexual violence perpetration: 0.07 vs 0.18 , p=ns
• School | F | 51% | • a theater production performed by peers, | • Violence in current relationship: 0.17 vs 0.16, p=ns
• community | W | 77% | • a poster contest for dating violence prevention, and | Mean score at 1 year, treated (n=7 schools) vs control (n=7 schools)
| AA | 19% | • 20 workshops for community service providers. | • Sexual violence perpetration: 0.15 vs 0.12 , p=ns
| O | 4% | Control group had the theater and community activities. | • Violence in current relationship: 0.15 vs 0.12, p=ns
| | | | (No measures of variation reported)
Project Towards No Drug Abuse (TND) (#4315) | Youth in continuation high schools | | • 9 session curriculum delivered in 3 weeks by trained health educators. | Perpetration of violence in past 12 months (slapped, punched, kicked, or beat up someone; threatened with a weapon; injured someone with weapon).
• School setting | M | 55% | • Each session lasted about 40 minutes. | Percent reporting any perpetration,Treated (n=14 schools) vs control (n=7 schools)
| F | 45% | • Curriculum designed to provide motivation, listening skills, information about chemical dependency, coping skills, peer norms, and decision making for students in continuation schools | Male | 60% vs 68%, p=ns
| W | 34% | | Female | 56% vs 55%, p=ns
| AA | 9% | | Adjusted odds ratio for control to treatment (95% CI), adjusted for baseline violence, survey procedure, and race/ethnicity:
| API | 4% | | Male | 1.23 (0.79, 1.90)
| L | 49% | | Female | 0.90 (0.56, 1.45)
| O | 4%
Triple-modality classroom program: (#5995) | Court referred adolescent males in a residential treatment facility. | | • Botvin life skills training | Violent behavior measured at 15 months follow-up based on a formula that assigned various weights to 8 of the 20 illegal offenses in the “Legal” problem section of the Adolescent Drug Abuse Diagnosis. (Treated: n=110; Control: n=91)
• Residential treatment facility setting | M | 100% | • Prothrow-Stith anti-violence program | Multiple regression analysis (Dependent variable: degree of violent offenses; covariates: age, years of education, race, occupation of head of household growing up with biological parents, been physically abused, and problem behavior and attitude) concluded:
| W | 17% | • Values clarification | Triple-modality classroom program did not show a significant advantage for reducing the degree of illegal or violent behavior.
| AA | 69% | • 55 classroom sessions (average 34 attended) | (No descriptive statistics reported)
| API | 3%
| O | 9%

Table 22 Program characteristics and findings for [underlined: secondary] interventions evaluated with [underlined: other study designs]

Program name and setting | Study design | Study population | | Description of program | Findings
(A) Secondary intervention reporting effectiveness, other study design
Positive Adolescents Choices Training (PACT) (#2563) | Non-Randomized Controlled Trial | Selected high risk African American middle school students | | Health promotion /risk reduction program targeted specifically to African American adolescents blending cognitive methods and skill building to address interpersonal violence. | Suspension attributed to violence (time period not specified).
• School setting | | Gender not specified | | • Small group training by interventionists at school sites | Percent suspension attributed to violence, Intervention (n=15) vs Partially Trained (n=6) vs Control (n=13):
| | AA | 100% | • Students received 37–38 50-minute sessions during the school year. | Before | 13% vs 33% vs 23%, p=0.57
| | | | | After | 0% vs 16% vs 54%, p=0.003
| | | | | Treated (n=15) vs Control (n=13):
| | | | | Before | 13% vs 23%, p=0.64
| | | | | After | 0% vs 54%, p=0.01
(B) Secondary intervention not reporting effectiveness, other study design
Selective serotonin reuptake inhibitors (SSRIs) treatment ((#1308) | Non-Randomized Controlled Trial | Psychiatrically hospitalized adolescents (not selected for aggressiveness | | To determine if a class of drugs, selective serotonin reuptake inhibitors (SSRIs), reduces aggressive behavior in adolescents | Mean±SD number of physical aggression episodes toward other people per week based on a modified Overt Aggression Scale
Setting | | Treated group: | | • Experimental group: patients with a minimum trial of 5 weeks with SSRIs initiated and completed during hospitalization | Mean±SD/week, On SSRI vs Off SSRI vs Control
• Psychiatric hospital | | M | 58% | • Control group: patients hospitalized for at least 4 weeks and did not receive an SSRI trial during hospitalization. | Disruptive | 0.49±0.38 vs 0.32±0.45 vs 0.64±0.71, p=ns (n=8 vs n=7 vs n=19)
| | F | 42% | • Starting dose: 15±5mg | Affective | 0.18±0.39 vs 0.23±0.43 vs 0.19±0.41, p=ns (n=9 vs n=5 vs n=15)
| | Ethnicity not given | | • dose raised 5mg every 4 days up to 25±10mg. | Psychotic | 2.21±2.54 vs 3.08±0.00 vs 1.49±2.33, p=ns (n=2 vs n=1, vs n=5)
| | | | | Mean±SD number of aggressive events between the first and last 2 weeks of the 5-week trial
| | | | | Mean±SD per week (n=13), On vs Off SSRIs:
| | | | | All subjects | 0.69±1.09 vs 0.50±0.88, p=ns
Conflict resolution model of family-systems intervention for individual parent-child (#5758) | Single group pre and post design | Junior high students with behavioral problems from recently dissolved families referred by teachers for special education | | Conflict resolution model of family systems intervention with parent (or guardian)/ child dyads. Services provided by agency counselor. | Frequency of physical aggression acts (measured by subscale of the Conflict Tactics scale) at 6-month follow-up (n=15).
Setting: | | M | 87% | • Dyads met weekly for 90 minutes with a counselor | Mean±SD at 6-month follow-up, after vs before 1.33±0.90 vs 1.73±0.88, p=ns
• Community agency | | F | 13% | • Dyads continued to meet for an average of 3 months
| | W | 53%
| | AA | 20%
| | L | 27%
Alternative to Suspension for Violent Behavior (ASVB) (#5301) | Non-Randomized Controlled study with pre and post intervention comparison | High school students who have been suspended for physical violence and their families | | • teaching social problem-solving and thinking skills | Rate of resuspension for fighting physical violence per year (measured by Physical Violence Index)
Setting: | | M | 82% | • family intervention | Percent re-suspended for fighting physical violence, treated (n=42) vs control (n=123) 7% vs 11%, p=ns
• Community agency | | F | 18% | • anger management
| | W | 74% | • 4 90-minute sessions
| | AA | 10%
| | API | 2%
| | L | 12%
| | O | 2%

Table 23 Program characteristics and findings for [underlined: tertiary] interventions evaluated with [underlined: randomized controlled trials]

Program name and setting | Study population | | Description of program | Findings
(A) Tertiary intervention reporting effectiveness, randomized controlled trial
Turning Point: Rethinking Violence (TPRV) (#0040) | First time male violent crime offender, ages 13–18 years, and their parents | | A collaborative program designed to expose, educate, and remediate first time violent offenders and their parents regarding the consequences of violence. The 4 key components are: | Conviction for violent offense within one year after first violent conviction and completion of court sanctions
Setting: | M | 100% | • trauma experience where participants visit a trauma center, a hospital morgue, and an autopsy room. | Violence conviction rate per year, treated (n=38) vs control (n=38):
• Health care center | W | 34% | • victim impact panel to expose participants to the aftermath of violence on the family and friends of the victim | 0.05 vs 0.33, p<0.05
| AA | 63% | • 6 weeks group therapy focusing on conflict resolution and anger management | (No measures of variation reported)
| O | 3% | • referrals for follow up mental health and health care services
| | | • Total face to face contact is approximately 14 hours
Multi-systemic therapy (MST) (#2644) | Juvenile offenders meeting DSM III R criteria for substance abuse or dependence and their families | | Multi-systemic Therapy focuses on individual, family, peer, school, and social network issues that contribute to identified problems. Treatment was characterized by: | 4-year aggressive crimes score (major assaults, minor assaults, and strong-armed robbery) (covariates: age and marijuana use at baseline)
• Community setting (home, school, neighborhood) | M | 76% | • low case loads per clinician allowing for intensive services to each family (average of 46 hours of service and 130 days of treatment) | 4-year conviction rate±SD, treated(n=43) vs control(n=37):
| F | 24% | • delivery of services in community settings (home, school, neighborhood) | 0.61±0.90 vs 1.36±2.21,
| W | 40% | • time- limited treatment (4–6 months) | unadjusted p<0.05
| AA | 60% | • 24/ 7 availability of therapists | adjusted p<0.05
| | | • provision of comprehensive services

Table 24 Program characteristics and findings for [underlined: tertiary] interventions evaluated with [underlined: other study designs]

Program name and setting | Study Design | Study Population | | Description of Program | Findings
(A) Tertiary intervention reporting effectiveness, other study design
Multi-modal treatment approach that utilized behavioral, cognitive-behavioral, and psychological skills training methods (#10786) | Non-Randomized Controlled Trial | Incarcerated male juvenile offenders | | A comparison of two programs. Group A was an earlier program and Group B was a later program that had been improved over time. | 1-year mean of violent incidents (assaults)
Setting: | Comparison of 2 programs | M | 100% | Group A characteristics: | Mean per year, Group B (n=36) vs Group A (n=41)
• Treatment facility | | AA | 34% | • on a behavioral point level system: | Violent incidents | | 1.5 vs 7.1, p<0.05
| | L | 21% | • allowed staff to use their discretion for assigning consequences for minor rule violations. | Assault on residents | | 0.0 vs 1.8, p<0.05
| | W | 42% | • individual counseling done by master's level clinicians | Assault on staff | | 0.0 vs 1.8, p<0.05
| | O | 3% | • group counseling assigned to those who seemed most motivated for treatment and did not pose serious behavioral problems. | Restraint for violence | | 0.5 vs 3.8, p<0.05
| | | | • participation mandatory but residents often gained release from school for medical or behavioral reasons. | Isolation for violence | | 0.8 vs 72.1, p<0.05
| | | | Group B characteristics: | (No measures of variation reported)
| | | | • treatment has been changed:
| | | | • behavioral contracts
| | | | • a gradual reintegration over a period of days or weeks into all aspects of the program
| | | | • individual and group counseling continued to be offered by Master's level clinicians with assistance by direct care staff.
Outpatient Behavioral Management of Aggressiveness in Adolescents - 3 programs combined (#7973) | Single group time series | Adolescents with oppositional-defiant disorder and aggressive behaviors | | Cognitive/behavioral services provided by a private psychologist included: | Actual violent contact with either hands or feet or using or throwing an object at parents, siblings, or any other person in home or other settings.
Setting: | | M | 81% | • parent training in the Real Economy System for Teens (REST) program | Each subject studied for 1 year. Total study period was 5 years.
• Home | | F | 19% | • parent implementation of the REST program in the home | Mean rate of aggressive acts for 20 weeks program duration (n=16):
• Psych health clinic | | Race/ethnicity not given | | • weekly individual cognitive therapy with the adolescent | Week | Mean rate | Week | Mean rate
| | | | • weekly brief consultation and coaching with parents | 1* | 4 | 11** | 5
| | | | • implementation of response cost program by parents to provide consequences for aggressive behavior | 2* | 3 | 12** | 3
| | | | • REST and response cost programs continue after aggression stops and therapy is discontinued | 3* | 2 | 13*** | 2
| | | | | 4* | 4 | 14*** | 2
| | | | | 5** | 3 | 15*** | 3
| | | | | 6** | 4 | 16*** | 1
| | | | | 7** | 3 | 17*** | 1
| | | | | 8** | 3 | 18*** | 0
| | | | | 9** | 4 | 19*** | 0
| | | | | 10** | 3 | 20*** | 0
| | | | | * Baseline period; ** Cognitive + REST period; ***Cognitive + REST + response cost period.
| | | | | Assuming one act per person, Chi-square for trend gives p=0.0014. Significance observed during the third period.
| | | | | (No measures of variation reported)
Multi-systemic Therapy (MST) - part of Missouri Delinquency Project (#1729) | Pre- and Post design with comparison group | Juvenile offenders at high risk for committing additional serious crimes | | Compared multi-systemic therapy (MST) to Individual Therapy (IT): | Findings from hierarchical multiple regression analysis, controlled for number of arrests for violent crimes prior treatment, on the number of arrests for violent crimes during 4-year follow-up [MST: 77 completers, 15 dropouts; IT: 63 completers, 21 dropouts]:
Setting: | | M | 68% | • present-focused, action oriented | Completers and dropouts
• Home | | F | 32% | • directly address intrapersonal and systemic factors | | F(2, 173) =11.74, p<0.0008
• Community | | W | 70% | • individualized and highly flexible | Completers only
| | AA | 30% | • mean of 24 hours of treatment | | F(2, 137)=8.66, p<0.003
| | | | | MST found equally effective with youths of different gender and ethnic background.
| | | | | (No measures of variation reported)
(B) Tertiary intervention not reporting effectiveness
Project Back-on-Track - An after school diversion program (#0692) | Non-Randomized Controlled Trial | Youths referred for violent offenses and met criteria for conduct disorder and their parents | | Multifaceted approach designed to target factors contributing to delinquent behavior and included child-specific interventions, parent specific interventions, and combined parent/child interventions. | Number of violent crimes committed at 12-month follow-up (assault, aggravated assault, attempted aggravated assault)
Setting | | M | 37% | • Youth participants met 2 hours per day after school, 4 days per week, for 4 weeks (total of 32 hours) | Number of violent crimes committed, treated (n=30) vs control (n=30):
• Child and adolescent psychiatry outpatient clinics | | F | 63% | • Parents/guardians required to attend 15 hours of interventions | | 2 vs 6, p=ns
| | W | 33% | • Treatment included group and family therapies, parent groups, educational sessions, community service projects, and empathy building exercises. | (No measures of variation reported)
| | AA | 63%
| | L | 3%
(C) Tertiary intervention with inconclusive finding
Stout Cottage Serious Sex Offenders Program (SSOP) (#6187) | Retrospective single group pre and post study | Convicted adolescent male rapists. All had a conduct disorder of an aggressive type | | • group therapy process | Recidivism rate of sexual assaults and criminal activities during 2-year post discharge from program (n=50)
Setting: | | M | 100% | • issues relate to delinquent and sex offenders | Convicted additional sexual assault:
• Secure residential facility for offenders | | Race/Ethnicity not given | | • both confrontational and supportive techniques | | | 5/50 | 10%
| | | | • 8 months process | Convicted another crime
| | | | • 3 one-hour sessions per week | | | 14/50 | 28%
| | | | | “The 10% and 28% can be considered as failure rates of the program.”

For this assessment, we considered an intervention program effective when at least one violent outcome indicator was found to change significantly at the p<0.05 level after the intervention. When no significant change in violent outcome indicators occurred at the p<0.05 level, we considered the program ineffective.

Of the 32 intervention studies, 13 were evaluated using a RCT, and 19 were evaluated using other study designs. Of the 13 RCTs, five incorporated primary prevention interventions (Bosworth, Espelage, 2000; Farrell, Meyer, 2003; Foshee, Bauman, 1998; Foshee, Bauman, 2000; Orpinas, Kelder, 2000; Perry, Komro, 2003); six incorporated secondary prevention interventions (Foshee, Bauman, 1998; Foshee, Bauman, 2000; Friedman, Terras, 2002; Hanlon, Bateman, 2002; Ludwig, Duncan, 2001; Moore, Armsden, 1998; Simon, Sussman, 2002); and two incorporated tertiary prevention interventions (Henggeler, Clingempeel, 2002; Scott, Tepas, 2002). Of the five RCTs used to evaluate primary prevention interventions, one (Farrell, Meyer, 2003) was reported to be effective (20 percent). Of the six RCTs for secondary prevention interventions, three (Hanlon, Bateman, 2002; Ludwig, Duncan, 2001; Moore, Armsden, 1998) were reported to be effective (50 percent). And of the two RCTs for tertiary prevention interventions (Henggeler, Clingempeel, 2002; Scott, Tepas, 2002), both were found to be effective (100 percent).

Of the 19 interventions using other study designs, 10 evaluated a primary prevention intervention, four evaluated secondary prevention interventions, and five evaluated tertiary prevention interventions. Four primary prevention interventions (40 percent) (DuRant, Treiber, 1996; Hawkins, Catalano, 1999; O'Donnell, Stueve, 1999; Reynolds, Temple, 2001), one secondary prevention intervention (25 percent) (Hammond and Yung, 1991), and three tertiary prevention interventions (60 percent) (Borduin, Mann, 1995; Morrissey, 1997; Stein, 1999) were reported to be effective. The findings of one tertiary intervention (Hagan, King, 1994) were reported to be inconclusive.

### Findings: Primary Interventions (RCTs)

All five RCTs testing primary prevention intervention were conducted in a school setting. None of these studies used the student as the unit of randomization; three used the school, one used a student team, and one used the homeroom as the unit of randomization. However, each study compared the pre-test characteristics of the experimental and control groups and adjusted for identified differences in analysis.

The one effective primary prevention intervention was “Responding in Peaceful and Positive Ways for 7th Graders,” (RIPP) (Farrell, Meyer, 2003). RIPP is a skills building program offered as an elective class in 12 weekly sessions. The curriculum focuses on conflict resolution and is implemented by trained interventionists. The study used the homeroom or a class period as the unit of randomization. Age and gender at pretest were significantly different between the RIPP and control students, and these differences were adjusted for in the analysis. The adjusted rate of violent behavior per 100 students at one year post-intervention was 11.2 for the experimental group and 23.1 for the control group, with a risk ratio (control to intervention) of 2.1 (95 percent CI: 1.1, 3.7, p<0.05).

Primary interventions reporting no significant effect on violence (RCT). The Safe Dates Program (Herrenkohl, Maguin, 2000; Herrera and McCloskey, 2001) was one of the four programs that reported no significant effect on violence. The Safe Dates Program focused on changing norms associated with partner violence, decreasing gender stereotyping, and improving conflict managing skills. The program was conducted by teachers in ten 45-minute sessions in conjunction with a theater production performed by peers, a poster contest, and 20 workshops for community service providers. This study used the school as the unit of analysis and compared seven experimental schools with seven control schools. Sexual violence was assessed using the mean score at one-month and one-year follow-up. Although all indicators demonstrated lower mean scores for the intervention, the difference did not reach statistical significance. No standard errors or confidence intervals were provided. The long-term effect of the program at one year post-intervention was also reported to be less than the effect one month after the intervention.

The second primary prevention intervention for which no significant effect on violence was reported was the Drug Abuse Resistance Education (DARE and DARE PLUS) program (Perry, Komro, 2003). The DARE program is a 10-week skill-building curriculum taught by police officers, and the DARE PLUS program adds a four-week peer-led parent involvement program, youth-led extracurricular activities, and neighborhood action teams to address neighborhood and school-wide issues. Growth curve analysis based on a three-level linear random-coefficients model was used to assess the efficacy of the program. Neither the DARE nor the DARE PLUS program, when compared to the control group, reported effectiveness in boys or girls. The growth rate (± SE) of self-reported violent behavior and intentions at 18-month follow-up was 0.35±0.08 per year for boys in the DARE PLUS program (n=1381) and 0.54±0.09 per year for boys in the control group (n=1093); p=0.06, a difference that did not reach statistical significance. For girls, the growth rate was 0.23±0.07 for the DARE plus program and 0.30±0.07 for the control group (p=0.24).

The third primary prevention intervention for which no significant effect on violence was reported was the Students Management Anger and Resolution Together (SMART) (Bosworth, Espelage, 2000). SMART is a computer-based multimedia program, used freely and independently by students during a single semester, that includes three major components: anger management, perspective taking, and dispute resolution. The article reported no difference in the mean aggression score (measured over the previous 30 days on four aggressive behaviors at four months after implementation) among boys: 16.1 for the experimental group (n=145) vs. 16.9 for the control group (n=90). No significant difference was reported among girls, either: 14.0 for the experimental group (n=176) vs. 13.9 for the control group (105).

The fourth primary prevention intervention that reported no significant effect on violence was the Student for Peace Program (Orpinas, Kelder, 2000). The program included formation of a school health promotion council, training of peer mediators and peer helpers, training of teachers in conflict resolution, a three-semester violence-prevention curriculum, and monthly newsletters for parents. The evaluation compared the mean reported frequency of fighting, fighting with injuries, and threatening to hurt between the experimental (n=1020 students in four intervention schools) and control (n=1226 students in four control schools) groups at one-year and two-year follow-up. All results were adjusted for academic performance and race/ethnic background and the differences between intervention and control conditions were adjusted for baseline measurement. None of the differences reached statistical significance. The most promising effect was among boys, where the difference between the treated and untreated groups was -8.8 (95 percent CI: -18.9, 1.3).

### Findings: Primary Interventions (Other study designs)

Four of 10 primary prevention interventions that used a study design other than a RCT reported effectiveness. Three were non-randomized controlled trials (NRCT) and one was a single group with pre- and post-test design.

One of the effective programs was the Seattle Social Development Project (Hawkins, Catalano, 1999), which used a NRCT design. The program consisted of a five-day teacher training session that covered proactive classroom management, interactive teaching, and cooperative learning; four hours of student training to recognize and resist social influences to engage in problem behaviors; and voluntary parent training classes in child behavior management skills. A full intervention, provided in grades one through six, consisted of five days of teacher in-service training each intervention year, developmentally appropriate parenting classes offered to parents when children were in grades one through three, five, and six, and developmentally adjusted social competence training for children in grades one and six. A late intervention, provided in grades five and six only, paralleled the full intervention for those grades. The study reported a significant reduction in lifetime violence behavior for the full intervention (-11.4; 95 percent CI: -21.3, -0.4; p=0.04; n=149 for the intervention group and n=206 for the control group) six years after the intervention, when participants were assessed at 18 years of age. No significant reduction was reported for the late intervention (-3.3; 95 percent CI: -12.0, 6.3; p=0.54; n=243 for the intervention group and n=206 for the control group).

The second program that reported effectiveness was the Chicago Child-Parent Center Program (CPC) (Reynolds, Temple, 2001). The CPC was a multi-component program focusing on education and family support. It consisted of year-round structured learning activities, a multifaceted parent program, outreach activities, ongoing staff development, health and nutrition services, and comprehensive school-age services. The intervention (n=989 children) included a half-day preschool for children ages three to four years ("early" intervention), a half- or full-day kindergarten, and school-age services in linked elementary schools for students ages six to nine years ("late" intervention). The comparison group (n=550) consisted of children who participated in alternative early childhood programs. The main outcome measure was the mean number of arrests for violent offenses between the ages of 10 and 18 years, adjusted for gender, race, risk index, early/late program, and site. The authors reported significantly fewer arrests for violent offenses between 10 and 18 years of age (adjusted mean score of 22 percent versus 35 percent, p=0.02; n=837 for the intervention group; n=444 for the control group) for the early (preschool) group, and no significant findings for the late (school-age) group (mean score of 28 percent versus 25 percent, p=0.64; n=729 for the intervention group and n=552 for the control group).

The third program that reported effectiveness was the Reach for Health Community Youth Service (CYS) Program (O'Donnell, Stueve, 1999). This study compared two interventions. The experimental intervention consisted of a 35-session, 6-month curriculum, delivered by trained instructors, that focused on drug and alcohol use, gender, and violence (including 10 sessions focusing on violence prevention) and a 3-hour-per-week community volunteer component (the actual CYS program). The control intervention included only the instructional curriculum. The experimental group consisted of 419 seventh and eighth graders from one school, and the control group consisted of 553 seventh and eighth graders from another school. Regression analyses were used to assess the influence of treatment condition on violent behavior outcomes, controlling for gender, race, grade, and social desirability. CYS was reported to be associated with a significant reduction in violent behavior among eighth graders, measured “during the past three months” and at six-months following the intervention (regression coefficient [SD]: -0.206 [0.096], p<0.05; n=445). No significant reduction in violence was reported among seventh graders who participated in the CYS program (regression coefficient [SD]: 0.102 [0.079]; p-value not significant; n=469).

Another primary prevention intervention study that reported effectiveness was a comparison of two violence prevention curricula for students in grades six through eight from two middle schools, the Violence Prevention Curriculum (146 students) and the Conflict Resolution Curriculum (63 students) (DuRant, Treiber, 1996). Both curricula consisted of ten 50-minute classroom sessions twice weekly over five weeks. The study compared the mean frequency of use of violence and the mean frequency of fighting during the previous 30 days assessed one week before and one week after participation in the intervention. For the Violence Prevention curriculum, the mean (SD) reported frequency of use of violence decreased from a level of 0.82 (1.79) before the intervention to 0.39 (1.28) after the intervention (p=0.004). For the Conflict Resolution curriculum, the mean (SD) reported frequency of use of violence was reduced from 0.73 (1.65) before the intervention to 0.51 (1.38) after the intervention (p=0.004).

Primary interventions reporting no significant effect on violence (non-RCT). Six primary prevention interventions that used a study design other than the RCT reported no significant effect. The first of these was the Improving Social Awareness-Social Problem Solving Project, a two-year program given to fourth and fifth grade students (Elias, Gara, 1991). Violence outcomes were measured six years after participation in the intervention, when students were in the ninth through eleventh grades. No sample sizes and no standard errors were reported in the article; thus the significance of the differences in the mean scores could not be determined. For boys, the discriminant analysis findings could not be used because they included both violent and non-violent outcomes. For girls, the discriminant function that significantly differentiated the experimental and control students did not include any of the three violent outcomes, indicating that the program had no significant effect on reducing violent behaviors in girls.

The second primary prevention intervention that reported no significant effect on violence was the Peaceful Conflict and Violence Prevention Curriculum (Durant, Barkin, 2001), designed for middle school students living in or around public housing. This program consisted of a 12-week, one-hour-per-week skill-building curriculum based on social cognitive theory. The intent of the program was to teach students to identify situations that could result in violence; and to teach a series of skills: avoidance, confrontation, problem-solving, communication and conflict resolution; the conflict cycle, the dynamics of a fight, and how to express anger without fighting. The study was conducted in four middles schools — two experimental (n=292 students) and two control (n=412 students). Use of violence during the previous 30 days was assessed using a 5-item scale and measured two weeks after participation in the intervention. The evaluation did not demonstrate significant differences between the experimental group [mean (SD) violence score: 1.1 (2.2); n=233] and the control group [mean (SD) violence score: 1.2 (2.4); (n=330)], p=0.63. The pre-test scores did not differ significantly between the two groups [1.4 (2.9) versus 1.1 (2.0); p=0.31].

The third primary prevention intervention that reported no significant effect on violence was the school-based hand-held metal detector program (Ginsberg C, 1993), a year round program in which a team of security officers visited schools weekly and scanned students at random. This study used a multiple cross-sectional study design in which it measured outcomes at two points in time but with different participants at each contact point. The percent of students that reported having been involved in a physical fight at least once during the school year following participation in the intervention was almost identical between the 243 students in the three experimental schools and the 1156 students in 12 control schools: 26 percent (95 percent CI: 14 percent-38 percent) for the intervention group and 24 percent (95 percent CI: 21 percent-27 percent) for the control group.

The fourth primary prevention intervention that reported no significant effect on violence was the Georgia Juvenile Justice Reform Act of 1994 (Risler, Sweatman, 1998). A study evaluated the impact of this new law, which mandated that adolescents, ages 13 through 17, be tried as adults if arrested for murder, voluntary manslaughter, rape, aggravated sexual battery, aggravated child molestation, aggravated sodomy, or firearm robbery. The study measured the impact of the law using a multiple cross-sectional study design for adolescents 13 through17 arrested for aggravated assault, armed robbery, sex offense, rape, and murder. The mean arrest rate pre- vs. post-intervention was 1833 versus 1726 for aggravated assault; 749 versus 857 for armed robbery; 394 versus 426 for sex offense; 121 versus 118 for rape; and 82 versus 83 for murder. None of the differences were statistically significant. The denominator unit for the rates and sample sizes were not reported.

The fifth primary prevention intervention for which no significant effect on violence was reported was the All Stars Character Education and Problem Behavior Prevention Program (Harrington, Giles, 2001) for sixth and seventh grade students, in which 629 students received the program and 739 did not. The 8-month program included whole classroom sessions, small-group sessions outside of class, and one-on-one sessions between instructor and student. Homework was used to increase interaction between students and parents. The study examined outcomes associated with different types of interventionists (i.e., specialist versus teachers versus control) among youth in three racial/ethnic groups: Whites, African-American, and Latino. The mean scores for ten items of reported violence towards other persons at one-year follow-up for students exposed to the different interventionist types were as follows: for African-American students, 1.54 with the specialist, 1.27 with teachers, and 1.59 with the control group, for Latino students, 2.07 with specialists, 1.22 with teachers, and 1.34 with the control group; for White students, 1.40 with specialists, 1.42 with teachers and 1.37 with the control group. No significant differences in mean violence score were reported at one-year follow-up, or for pre- vs. post-test, regardless of the type of interventionist.

The sixth primary prevention intervention for which no significant effect on violence was reported was a traditional martial arts training program (Zivin, Hassan, 2001). A martial arts master taught the program three times a week over a 10-week period. The mean ±SD 9-item violence score rated by the teacher at four-month follow-up was 3.20±1.46 for the experimental group (n=31) and 3.34±1.05 for the control group (n=17). These differences were not statistically significant.

### Findings: Secondary Interventions (RCTs)

Of the six RCTs for secondary prevention interventions, three were reported to be effective (Hanlon, Bateman, 2002; Ludwig, Duncan, 2001; Moore, Armsden, 1998) and three reported no significant effect in reducing youth violence (Friedman, Terras, 2002; Herrenkohl, Maguin, 2000; Herrera and McCloskey, 2001; Simon, Sussman, 2002).

One of the three secondary prevention RCTs for which effectiveness was reported was the Moving to Opportunity (MTO) demonstration project, a housing mobility experiment to study the effects of relocating families from high- to low poverty neighborhoods on juvenile crime. One experimental group consisted of 148 families with Section 8 housing vouchers that could be redeemed for housing only in census tracts with 1990 poverty rates less than 10 percent. These families also received housing-search assistance and life-skills counseling. Another experimental group consisted of 92 families with regular Section 8 housing vouchers that provided subsidies to lease private-market housing but with no limitations on where they could be redeemed. The control group consisted of 96 families on the MTO waiting list. The prevalence of arrests for violent crime during the post-program period was 2.4 percent for the MTO group and 5.0 percent for the control group, a difference (±SE) of 2.6 percent (±1.4 percent), which was statistically significant (p<0.05). The prevalence was 1.9 percent for the Section 8 group and 3.9 percent for the control group, a difference (±SE) of 2.0 percent (±1.1 percent), also statistically significant (p<0.05). The incidence rate per 100 teens for violent-crime arrests was 2.5 for the MTO program and 5.7 for the control program, a difference (±SE) of 3.2 (±1.5), which was statistically significant (p<0.01). The incidence rate per 100 teens was 1.9 for the Section 8 program and 4.3 for the control program, a difference (±SE) of 2.4 (±1.2), which was statistically significant at p<0.01.

Another secondary prevention intervention for which effectiveness was reported was the Early Community-Based Intervention Program for the prevention of substance abuse and other delinquent behaviors (Hanlon, Bateman, 2002) for inner-city youth at high risk of adopting a delinquent lifestyle. The one-year program consisted of individual counseling; group mentoring sessions available four to five days a week after school including structured skill building activities, educational and recreational field trips, and holiday celebrations; and informal parent discussions and parent-child social events. A Poisson regression analysis that compared self-reported violent behaviors between 235 experimental subjects and 193 control subjects during the preceding six months at one-year follow-up revealed significant treatment effects (p=0.003). Means and standard errors for this particular indicator were not provided.

The third secondary prevention intervention for which effectiveness was reported was the Childhaven's Therapeutic Child-Care Program (formerly the Seattle Day Nursery) (Moore, Armsden, 1998) for abused, neglected, and at-risk infants and toddlers and their parents. The program consisted of voluntary parent education, counseling, support groups, and linkage to professional services. The average length of participation was 23 months. The experimental group included 32 children and the control group included 29 children. Nearly two-thirds (n=21) of the parents in the experimental group were substantively engaged in the program, while 25 percent (n=8) did not participate at all. At 12-year follow-up, 21 of the 32 original families in the experimental group and 14 of the 29 original families in the control group were located. During the 12-year follow-up period, significant reduction in mean violent arrests (0.04 vs. 0.30, respectively; p<0.05) and in the incidence of fighting reported in juvenile court records and school files (12 percent vs. 36 percent, respectively; p<0.05) were observed in the experimental group compared to the control.

Secondary interventions reporting no significant effect on violence (RCT). A secondary prevention intervention for which no significant effect on violence was reported was the Safe Dates Program, which also conducted a primary intervention, described above. The secondary intervention targeted eighth- and ninth-grade students who were perpetrators of violence (Herrenkohl, Maguin, 2000; Herrera and McCloskey, 2001). The Safe Dates Program focused on changing norms associated with partner violence, decreasing gender stereotyping, and improving conflict managing skills. The intervention was delivered in ten 45-minute sessions conducted by teachers together with a theater production performed by peers and included a poster contest and 20 workshops for community service providers. The program also had a primary intervention program component (reported in the previous section). The evaluation of the secondary intervention component focused on perpetrators of violence. The unit of analysis was the school: seven schools carried out the intervention and seven served as controls. The one-month mean score for sexual violence perpetration was 0.07 for the experimental group and 0.18 for the control group, and the one-year mean score was 0.15 for the experimental group and 0.12 for the control group. The one-month mean score for violence reported in a current relationship was 0.17 for the experimental group and 0.16 for the control group; the one-year mean score was 0.15 for the experimental group and 0.12 for the control group. The differences were not statistically significant at a significance level of p less than 0.05.

Another secondary prevention program for which no significant effect on violence was reported was the project Towards No Drug Abuse (TND) (Simon, Sussman, 2002) for youth in continuation high schools. The program consisted of a curriculum of nine, 40-minute sessions delivered over three weeks by trained health educators and was designed to provide motivation, listening skills, information about chemical dependency, coping skills, information about peer norms, and help with decision-making. The study enrolled 14 experimental schools and 7 control schools. The total number of students involved in the program was 850 (no gender breakdown was provided for the sample). Sixty percent of the boys and 56 percent of the girls in the experimental schools, compared with 68 percent of boys and 55 percent of the girls in the control schools reported violence perpetration in the past 12 months. Violence perpetration included slapping, punching, kicking, beating up someone, threatening with a weapon, and injuring someone with a weapon. These differences were not statistically significant at a significance level of p less than 0.05.

The third secondary prevention program for which no significant effect on violence was reported was the Triple-Modality Classroom Program (Friedman, Terras, 2002) for court-referred adolescent males in a residential treatment facility. The intervention included 55 classroom sessions focused on helping participants (1) understand the effects of drugs, alcohol and tobacco on health and behavior and learn how to cope with temptations and pressures to start or to continue using drugs; improve self expression; learn how to control and direct one's behavior, and achieve personal and social skills; (2) control tendencies toward violence; and (3) clarify their values, explore other values, and attempt to develop and identify with a set of socially acceptable and desirable values. Participants attended an average of 34 sessions. The program studied 201 adolescent males — 110 in the intervention group and 91 in the control group. Multiple regression analysis in which the degree of violent offenses was the dependent variable, and age, years of education, race, occupation of head of household, growing up with biological parents, having been physically abused, and problem behavior and attitude were the independent variables reported no significant advantage of the program (t-statistic: +0.44, not statistically significant at p<0.05).

### Findings: Secondary Interventions (Other study designs)

Four secondary prevention interventions were studied using study designs other than RCT. Effectiveness was reported for one of the four, the Positive Adolescents Choices Training (PACT) Program. This program targeted high-risk African-American middle school students; 21 students received the intervention and 13 students did not (Hammond and Yung, 1991). The program blended cognitive methods and skill building to address interpersonal violence delivered in small groups by trainers at school sites in 37 to 38, 50-minute sessions during the school year. Of the 21 students who received the intervention, 15 attended all the sessions and six attended only some of the sessions. No pre-intervention difference was found between students who attended all the sessions, students who attended some of the sessions, and the control students with respect to suspension attributable to violence (13 percent, 33 percent, 23 percent, respectively; p=0.64). However, significant post-intervention differences were observed (0 percent, 16 percent, 54 percent, respectively; p=0.003). The time period for the outcome measure was not specified.

Secondary interventions reporting no significant effect on violence (non-RCT). The Selective Serotonin Reuptake Inhibitors (SSRIs) Treatment Program for psychiatrically hospitalized adolescents (Constantino, Liberman, 1997) was one of three programs for which no effectiveness was reported. The adolescents, who were not selected for aggressiveness, were divided into an experimental group of 19 patients who received SSRI trial for 5 weeks, and a control group of 39 patients who were hospitalized for at least four weeks but did not receive an SSRI trial. The mean number of physical aggression episodes per week for 13 experimental patients was 0.69 on the medication and 0.50 off the medication, a difference that was not statistically significant. The study also compared the mean number of episodes of physical aggression per week between the experimental and the control patients, and controlled for disruptive behavior as well as affective and psychotic disorders. No significant differences were observed, likely due to inadequate power.

The second secondary prevention intervention for which no significant effect on violence was reported was the Conflict Resolution Model of Family-Systems Intervention for Individual Parent-Child Dyads (Dykeman, 2003). This intervention was targeted to students with behavioral problems from recently dissolved families who were referred by special education teachers. Fifteen parent-child dyads met weekly for 90 minutes with a counselor for an average of three months in a community agency. The mean number of physical aggression acts (±SD) at six-month follow-up was 1.33±0.90 compared with 1.73±0.88 prior to intervention (p=0.11).

The third secondary prevention intervention for which no effectiveness was reported was the Alternative to Suspension for Violent Behavior (ASVB) (Breunlin, Bryant-Edwards, 2002) for high school students who have been suspended for physical violence. The program, which also included families, consisted of four, 90-minute sessions dedicated to teaching social problem-solving and thinking skills, family intervention, and anger management. The evaluation was a NRCT with pre- and post-intervention comparison. The percent of re-suspension for physical violence (i.e., fighting) per year was 7 percent for the experimental group (n=42) compared with 11 percent for the control group (n=123), a difference that was not statistically significant.

### Findings: Tertiary Interventions (RCTs)

We reviewed two RCTs for tertiary interventions. Effectiveness was reported for both. One was the Turning Point Rethinking Violence (TPRV) Program (Scott, Tepas, 2002), a collaborative program designed to educate, and remediate first-time male violent crime offenders — ages 13 to18 years — and their parents regarding the consequences of violence. The program consisted of four key components: trauma experience where participants visit a trauma center, a hospital morgue, and an autopsy room; victim impact panel, to expose participants to the impact of violence on the family and friends of the victim; six weeks of group therapy focusing on conflict resolution and anger management; and referrals for follow-up mental health and health care services. The total face-to-face contact with program activities was approximately 14 hours. The recidivism rate, defined as conviction rate for violent offenses within one year after first violence conviction and completion of court sanctions, was 0.05 for the experimental group (n=38) and 0.33 for the control group (n=38) (p<0.05).

The other tertiary intervention for which effectiveness was reported was the Multi-Systemic Therapy (MST) Program for juvenile offenders meeting the DSM III R criteria for substance abuse or dependence (Henggeler, Clingempeel, 2002). Treatment, which included families, was characterized by intensive family services delivered in community settings (home, school, neighborhood) and the provision of comprehensive services over a 4 to 6 month period with therapists who maintained low case loads and were available on a 24-hour-a-day, 7-day-a-week basis. The mean ±SD four-year conviction rate of aggressive crimes was 0.61±0.90 for the experimental group (n=43) and 1.36±2.21 for the control group (n=37) (p<0.05).

### Findings: Tertiary Interventions (Other study designs)

Five tertiary prevention interventions with other study designs were also evaluated. Effectiveness was reported for three of these programs, whereas findings from the evaluation of the fourth program were inconclusive.

One of the tertiary interventions for which effectiveness was reported was the Multi-Modal Treatment Approach, which used behavioral, cognitive-behavioral, and psychological skills training methods (Morrissey, 1997) for incarcerated male juvenile offenders. This trial compared an improved treatment approach (n=36) with an earlier version of the treatment program (n=41). The evaluation reported a one-year mean of violent incidents for each of five types of assaults — violent incidents, assault on residents, assault on staff, restraint for violence, and isolation for violence. Significant differences were reported for all five types of assault between the intervention group and the group exposed to the earlier version of the program. The one-year incidence for violent incidents was 1.5 for the intervention group and 7.1 for the control group (p<0.05). Other findings are provided in Table 24

Another tertiary prevention intervention for which effectiveness was reported was the Outpatient Behavioral Management of Aggressiveness in Adolescents (Stein, 1999), a single group, pre- and post-trial assessment that enrolled 16 adolescents with oppositional-defiant disorder and aggressive behaviors. The program consisted of three components — individual cognitive therapy for adolescents, the Real Economy Systems for Teens (REST) program, and the response cost program for parents to introduce the idea of consequences for aggressive behavior. Parental reports of their observations during a 20-week period showed a significant reduction in the mean rate of aggressive acts during the third phase of the program, when the response cost program was added to the cognitive and REST components of the program. After aggression stopped, weekly office visits were discontinued but the REST and response cost programs remained in effect. The parents were instructed to continue observations until the end of the program to secure stabilization of the behaviors. Parents were followed up by phone at one year; however, the findings were not reported.

The third tertiary intervention for which effectiveness was reported compared a Multi-Systemic Therapy (MST) Program (n=77) to an individual therapy (IT) program (n=63) targeting juvenile offenders at high risk for committing additional serious crimes. Findings from the hierarchical multiple regression analysis on the number of arrests for violent crimes during the four-year follow-up period showed significant effectiveness of the MST program, p<0.003. The program was found to be equally effective with youth of both genders and of differing ethnic backgrounds.

Tertiary interventions reporting no significant effect on violence (non-RCT). One study of a tertiary prevention intervention reported no significant effect on violence. The Project Back-on-Track Program was a multi-faceted after-school diversion program for youths referred for violent offenses, who met criteria for conduct disorder (Myers, Burton, 2000). Treatment included group and family therapies, parent groups, educational sessions, community service projects, and empathy-building exercises. Youth participants met for 32 hours over four weeks, and parents or guardians were required to attend 15 hours of interventions. This program used a NRCT design in which 30 youths participated in the intervention and 30 acted as controls. The evaluation assessed the number of violent crimes (assault, aggravated assault, and attempted aggravated assault) committed over a 12-month period. Two crimes were reported for the intervention group compared with six for the control group, but the difference did not reach statistical significance.

The Stout Cottage Serious Sex Offenders Program (SSOP) (Hagan, King, 1994) was a tertiary prevention program targeting convicted adolescent male rapists. The program used both confrontational and supportive techniques in a group therapy process that met three times a week over an eight-month period. The recidivism rate during the program's two-year post discharge period was 5/50 or 10 percent for convicted sexual assaults and 14/50 or 26 percent for other convicted crimes. However, without a control group, the relevance of the recidivism rates was difficult to interpret. Therefore, we considered the findings of this study inconclusive.

### Safety of interventions

The outcome indicators used for our analysis included both the reduction of violent behaviors and adverse health effects and safety. However, only three of the 32 studies considered the issue of intervention safety. The NRCT of the Selective Serotonin Reuptake Inhibitors (SSRIs) treatment program reported adverse effects of the treatment (Constantino, Liberman, 1997). Of the 19 treated patients, two experienced minor adverse effects of SSRIs. One experienced dose-dependent tremor and insomnia and another developed mild recurrent headaches. Neither patient required discontinuation of drugs. The other two studies, Student for Peace (Orpinas, Kelder, 2000) and Violence Prevention Curriculum for Adolescents and Conflict Resolution Curriculum for Youth Provider (DuRant, Treiber, 1996) included “frequency of injuries due to fights” as an outcome measure. No significant differences were found in either study between the treated and the control groups in the frequency of fighting resulting in injury.

## Summary of Findings

For this assessment we used the vote-counting method (described in Chapter 2) because better methods of synthesis were not possible due to the heterogeneity of the intervention studies. For example, in terms of the level of intervention analysis, within study comparisons of interventions aimed at different levels would be the strongest level of evidence (since study level variables are controlled for), but that these did not exist. Given the absence of such data, some measure of the effectiveness of interventions at different levels could be made by simply assessing the number of effective studies at each level, although this is an imperfect measure. Given that this is the best we could do, however, we noted that the effectiveness of the programs appeared to be associated with the level of intervention, that is, tertiary interventions were more likely to be associated with change than were primary interventions. The distinctions in apparent effectiveness among the three levels of intervention were most clearly shown with RCTs. A descriptive summary of the effectiveness of intervention programs by the level of intervention and by study design for 31 studies is provided in Table 25. The one study that did not report conclusive findings was excluded.

Table 25 Summary of findings ^a^ for Key Questions #3, #4 and #5

Level of intervention | Randomized controlled trial (RCT) | | Design other than RCT | | Total ^b^
Primary | Reporting effectiveness | 1 (25%) | Reporting effectiveness | 4 (40%) | Reporting effectiveness | 5 (33%)
| Not reporting effectiveness | 4 | Not reporting effectiveness | 6 | Not reporting effectiveness | 10
Secondary | Reporting effectiveness | 3 (50%) | Reporting effectiveness | 1 (25%) | Reporting effectiveness e | 4 (40%)
| Not reporting effectiveness | 3 | Not reporting effectiveness | 3 | Not reporting effectiveness | 6
Tertiary | Reporting effectiveness | 2 (100%) | Reporting effectiveness | 3 (75%) | Reporting effectiveness | 5 (83%)
| Not reporting effectiveness | 0 | Not reporting effectiveness | 1 | Not reporting effectiveness | 1
All levels | Reporting effectiveness | 6 (46%) | Reporting effectiveness | 8 (44%) | Reporting effectiveness | 14 (45%)
| Not reporting effectiveness | 7 | Not reporting effectiveness | 10 | Not reporting effectiveness | 17

a A finding was considered effective when one or more violent outcome indicators in the study reported p<0.05. Number (percent) of studies are reported here by finding, level and study design.

b Excluded one study that reported inconclusive findings.

## Key Question #4: Where evidence of safety and effectiveness exists, are there other outcomes beyond reducing violence? If so, what is known about effectiveness by age, sex, and race/ethnicity?

Similar to our assessment with the level of interventions, within study comparisons are the strongest analytic approach to answer this question. However, none of the studies provided the information needed to evaluate differential effects by age, gender, or race/ethnicity. Here we provide a summary of the findings we reported in the Results section for Key Question #3 for those studies that reported effectiveness of intervention programs by gender and/or ethnicity.

For primary interventions, three of the five RCTs reported findings for boys and girls — the DARE and DARE PLUS program (Perry, Komro, 2003), the Students Management Anger and Resolution Together program (Bosworth, Espelage, 2000), and the Student for Peace Program (Orpinas, Kelder, 2000). None of the evaluations of these programs compared the effectiveness of the intervention for boys vs. girls; thus, no findings on differential effectiveness can be reported. Neither of the other two RCTs reported their findings by gender, but they adjusted their findings by gender and other covariates. One of the 10 non-RCT studies reported findings separately for boys and girls (Elias, Gara, 1991). However, the discriminant analysis findings could not be used for boys because they included both violent and non-violent outcomes. For girls, the discriminant function that significantly differentiated the experimental and control students did not include any of the three violent outcomes, indicating that the program had no significant effect in reducing violent behaviors in girls.

None of the RCTs of primary interventions reported their findings by race/ethnicity; however, one study (Orpinas, Kelder, 2000) adjusted its findings by race/ethnicity but did not show the relative effectiveness by race/ethnicity. One of the 10 non-RCT studies reported findings by race/ethnicity (Harrington, Giles, 2001) but found no effectiveness for Whites, African-Americans, or Latinos; no differential effectiveness among ethnic groups within the study was reported

For secondary interventions, only one of six RCTs reported its findings by gender (Simon, Sussman, 2002) and it reported no program effectiveness in either gender group. One RCT did not report its findings by gender or race/ethnic groups but instead adjusted its findings by age, race and other covariates.

For tertiary interventions, only one of the six studies, the Multi-Systemic Therapy program (Borduin, Mann, 1995), reported its findings by gender and ethnicity. The program was associated with equivalent changes in violent behavior for youth of both genders and of different ethnic backgrounds.

We provide a descriptive summary of the effectiveness of interventions by gender and predominant racial/ethnic groups in Table 26.

Table 26 Summary of program effectiveness by gender and predominant race/ethnicity in study population

Level of intervention | Effectiveness of program | Male and female | Male | Total
(A) Effectiveness of intervention by gender of study population
Primary Intervention | Reporting effectiveness | 4 (40%) | 0 (0%) | 4 (36%)
| Not reporting effective | 6 (60%) | 1 (100%) | 7 (64%)
| Subtotal ^a^ | 10 | 1 | 11
Secondary Intervention | Reporting effectiveness | 2 (29%) | 0 (0%) | 2 (25%)
| Not reporting effective | 5 (71%) | 1 (100%) | 6 (75%)
| Subtotal ^a^ | 7 | 1 | 8
Tertiary Intervention | Reporting effectiveness | 3 (75%) | 2 (100%) | 5 (83%)
| Not reporting effective | 1 (25%) | 0 (0%) | 1 (17%)
| Subtotal ^a^ | 4 | 2 | 6
All levels | Reporting effectiveness | 9 (43%) | 2 (50%) | 11 (44%)
| Not reporting effective | 12 (57%) | 2 (50%) | 14 (56%)
| Total ^a^ | 21 | 4 | 25

a Excluded studies that did not report gender distribution. Primary group had 4 unknowns, secondary group had 2 unknowns and tertiary group had 1 unknown, a total of 7 unknowns. The study that reported inconclusive findings was excluded.

Table 26 Summary of program effectiveness by gender and predominant race/ethnicity in study population

Level of intervention | Effectiveness of program | White | African-American | Latino | Total
(B) Effectiveness of intervention by predominant race/ethnic group ^b^
Primary Intervention | Reporting effectiveness | 1 (20%) | 4 (80%) | 0 (0%) | 5 (45%)
| Not reporting effective | 4 (80%) | 1 (20%) | 1 (100%) | 6 (55%)
| Subtotal ^a^ | 5 | 5 | 1 | 11
Secondary Intervention | Reporting effectiveness | 0 (0%) | 3 (75%) | 0 (0%) | 3 (38%)
| Not reporting effective | 3 (100%) | 1 (25%) | 1 (100%) | 5 (62%)
| Subtotal ^a^ | 3 | 4 | 1 | 8
Tertiary Intervention | Reporting effectiveness | 2 (100%) | 2 (67%) | 0 (------) | 4 (80%)
| Not reporting effective | 0 (0%) | 1 (33%) | 0 (------) | 1 (20%)
| Subtotal ^a^ | 2 | 3 | 0 (------) | 5
All levels | Reporting effectiveness | 3 (30%) | 9 (75%) | 0 (0%) | 12 (50%)
| Not reporting effective | 7 (70%) | 3 (25%) | 2 (100%) | 12 (50%)
| Total ^a^ | 10 | 12 | 2 | 24

a Excluded studies that did not report gender distribution. Primary group had 4 unknowns, secondary group had 2 unknowns and tertiary group had 1 unknown, a total of 7 unknowns. The study that reported inconclusive findings was excluded.

b The race/ethnicity group that had the highest percentage in the study population (or mode).

## Key Question #5: What are commonalties of the interventions that are effective, and those that are ineffective?

Similar to the assessment of effectiveness by gender and racial/ethnic groups, it is impossible to draw any conclusions about relative effectiveness of the interventions by program characteristics, because no one study explicitly compared effectiveness by characteristics of the interventions. Using the vote-counting method, we examined four characteristics of the intervention program: the setting in which the intervention took place; whether the intervention was a single or a multi-component intervention; the duration of the intervention; and the school level at which the intervention was implemented. Overall, we did not observe any significant variations in intervention effectiveness according to the delivery setting, between single and multi-component interventions, among interventions of different duration, or among interventions implemented at different school levels. However, we did observe that secondary interventions that lasted a year or longer were more likely to be found effective (as reported in four of four articles) than those that lasted six months or less (as reported in five of five articles). We provide a descriptive summary of the reported effectiveness of the interventions by the selected program characteristics in Table 27.

Table 27 Summary of effectiveness of interventions by selected program characteristics

Level of intervention | Effectiveness of program | School | Community | Home | Other | School & Community | Home & Community | Home & Facility | Total
(A) Effectiveness of intervention by setting
Primary Intervention | Reporting effectiveness | 3 (30%) | | | 0 (0%) | 2 (67%) | 0 (0%) | | 5 (33%)
| Not reporting effectiveness | 7 (70%) | | | 1 ^b^ (100%) | 1 (33%) | 1 (100%) | | 10 (67%)
| Subtotal | 10 | | | 1 | 3 | 1 | | 15
Secondary Intervention | Reporting effectiveness | 1 (50%) | 3 (60%) | | 0 (0%) | 0 (0%) | | | 4 (40%)
| Not reporting effectiveness | 1 (50%) | 2 (40%) | | 2 ^c^ (100%) | 1 (100%) | | | 6 (60%)
| Subtotal | 2 | 5 | | 2 | 1 | | | 10
Tertiary Intervention | Reporting effectiveness | | | 1 (100%) | 2 ^d^ (67%) | | 1 (100%) | 1 (100%) | 5 (83%)
| Not reporting effectiveness | | | 0 (0%) | 1 ^e^ (33%) | | 0 (0%) | 0 (0%) | 1 (17%)
| Subtotal ^a^ | | | 1 | 3 | | 1 | 1 | 6
All levels | Reporting effectiveness | 4 (33%) | 3 (60%) | 1 (100%) | 2 (33%) | 2 (50%) | 1 (50%) | 1 (100%) | 14 (45%)
| Not reporting effectiveness | 8 (67%) | 2 (40%) | 0 (0%) | 4 (67%) | 2 (50%) | 1 (50%) | 0 (0%) | 17 (55%)
| Total ^a^ | 12 | 5 | 1 | 6 | 4 | 2 | 1 | 31

a The study that reported inconclusive findings was excluded.

b State.

c One residential treatment facility and one psychiatric hospital.

d One health care center and one treatment facility.

e Psychiatric outpatient clinics.

f One study that did not report on duration excluded.

g One included kindergarten

h Two included 6th grade and one included 9th grade.

i One included 9th grade

j One included 9 year olds.

Table 27 Summary of effectiveness of interventions by selected program characteristics

Level of intervention | Effectiveness of program | Single | Multiple | Total
(B) Effectiveness of intervention by single or multiple component program
Primary Intervention | Reporting effectiveness | 2 (25%) | 3 (43%) | 5 (33%)
| Not reporting effectiveness | 6 (75%) | 4 (57%) | 10 (67%)
| Subtotal | 8 | 7 | 15
Secondary Intervention | Reporting effectiveness | 1 (20%) | 3 (60%) | 4 (40%)
| Not reporting effectiveness | 4 (80%) | 2 (40%) | 6 (60%)
| Subtotal | 5 | 5 | 10
Tertiary Intervention | Reporting effectiveness | 2 (100%) | 3 (75%) | 5 (83%)
| Not reporting effectiveness | 0 (0%) | 1 (25%) | 1 (17%)
| Subtotal ^a^ | 2 | 4 | 6
All levels | Reporting effectiveness | 5 (33%) | 9 (56%) | 14 (45%)
| Not reporting effectiveness | 10 (67%) | 7 (44%) | 17 (55%)
| Total ^a^ | 15 | 16 | 31

a The study that reported inconclusive findings was excluded.

b State.

c One residential treatment facility and one psychiatric hospital.

d One health care center and one treatment facility.

e Psychiatric outpatient clinics.

f One study that did not report on duration excluded.

g One included kindergarten

h Two included 6th grade and one included 9th grade.

i One included 9th grade

j One included 9 year olds.

Table 27 Summary of effectiveness of interventions by selected program characteristics

Level of intervention | Effectiveness of program | <3 months | 3–<6 months | 6–<12 months | ≥ 12 months | Total
(C) Effectiveness by duration of program
Primary Intervention | Reporting effectiveness | 3 (50%) | 0 (0%) | 1 (50%) | 1 (20%) | 5 (33%)
| Not reporting effectiveness | 3 (50%) | 2 (100%) | 1 (50%) | 4 (80%) | 10 (67%)
| Subtotal | 6 | 2 | 2 | 5 | 15
Secondary Intervention | Reporting effectiveness | 0 (0%) | 0 (0%) | | 4 (100%) | 4 (44%)
| Not reporting effectiveness | 4 (100%) | 1 (100%) | | 0 (0%) | 5 (56%)
| Subtotal ^f^ | 4 | 1 | | 4 | 9
Tertiary Intervention | Reporting effectiveness | 2 (100%) | 2 (100%) | 0 (0%) | 1 (100%) | 5 (83%)
| Not reporting effectiveness | 0 (0%) | 0 (0%) | 1 (100%) | 0 (0%) | 1 (17%)
| Subtotal ^a^ | 1 | 2 | 1 | 1 | 6
All levels | Reporting effectiveness | 5 (42%) | 2 (40%) | 1 (33%) | 6 (60%) | 14 (47%)
| Not reporting effectiveness | 7 (58%) | 3 (60%) | 2 (67%) | 4 (40%) | 16 (53%)
| Total ^a, f^ | 12 | 5 | 3 | 10 | 30

a The study that reported inconclusive findings was excluded.

b State.

c One residential treatment facility and one psychiatric hospital.

d One health care center and one treatment facility.

e Psychiatric outpatient clinics.

f One study that did not report on duration excluded.

g One included kindergarten

h Two included 6th grade and one included 9th grade.

i One included 9th grade

j One included 9 year olds.

Table 27 Summary of effectiveness of interventions by selected program characteristics

Level of intervention | Effectiveness of program | Preschool | Elementary school | Middle school | High school | Middle & High schools | Total
(D) Effectiveness by School Level of Implementation
Primary Intervention | Reporting effectiveness | 1 ^g^ (100%) | 1 (50%) | 3 (30%) | 0 (0%) | 0 (0%) | 5 (33%)
| Not reporting effectiveness | 0 (0%) | 1 (50%) | 7 ^h^ (70%) | 1 (100%) | 1 (100%) | 10 (67%)
| Subtotal | 1 | 2 | 10 | 1 | 1 | 15
Secondary Intervention | Reporting effectiveness | 1 (100%) | | 1 (33%) | 0 (0%) | 2 ^j^ (67%) | 4 (40%)
| Not reporting effectiveness | 0 (0%) | | 2 ^I^ (67%) | 3 (100%) | 1 (33%) | 6 (60%)
| Subtotal | 1 | | 3 | 3 | 3 | 10
Tertiary Intervention | Reporting effectiveness | | | | 2 (100%) | 3 (75%) | 5 (83%)
| Not reporting effectiveness | | | | 0 (0%) | 1 ^j^ (25%) | 1 (17%)
| Subtotal | | | | 2 | 4 | 6
All levels | Reporting effectiveness | 2 (100%) | 1 (50%) | 4 (31%) | 2 (33%) | 5 (62%) | 14 (45%)
| Not reporting effectiveness | 0 (0%) | 1 (50%) | 9 (69%) | 4 (67%) | 3 (38%) | 17 (55%)
| Total | 2 | 2 | 13 | 6 | 8 | 31

a The study that reported inconclusive findings was excluded.

b State.

c One residential treatment facility and one psychiatric hospital.

d One health care center and one treatment facility.

e Psychiatric outpatient clinics.

f One study that did not report on duration excluded.

g One included kindergarten

h Two included 6th grade and one included 9th grade.

i One included 9th grade

j One included 9 year olds.

Although we intended to perform meta-analysis to pool the findings of homogeneous studies, we were unable to find such a homogeneous stratum of studies. We also planned to use meta-regression to identify the characteristics of interventions that were associated with the effectiveness of programs. However, due to the inadequacy and inconsistency of reporting measures of variation, we could not conduct a meta-regression analysis.

### Study Quality of Studies for Key Questions #3, #4 and #5

Of the 32 interventions evaluated, 13 were RCTs, five on primary interventions, six on secondary interventions, and two on tertiary interventions. Eight criteria were used to evaluate the study quality of RCTs: 1) was randomization method adequate to assemble comparable groups? 2) was blinding or concealment method used in treatment allocation? 3) was blinding or concealment method used in outcome assessment? 4) were primary and secondary outcomes reliable and valid? 5) was the comparability of groups maintained throughout the study (80 percent or greater)? 6) was intent-to-treat analysis or similar analytical method used? 7) were important outcomes studied? 8) were all potential confounders accounted or controlled for? Since we selected only those studies with relevant violence outcomes, criterion #7 was common to all studies. In our evaluation we combined criteria #2 and #3 into one. Therefore, we evaluated the quality of the 13 RCTs using six criteria; the findings are presented in Table 28.

Table 28 OMAR study quality criteria applied to randomized controlled trials

Level | Intervention | Article ID# | Unit of randomization | OMAR Study Quality Criteria^a^
| | | | Adequate randomization^b^ | Blinded enrollment and outcome | Validated instrument | Follow-up >=80%^c^ | Intent-to-treat analysis^c^ | Controlled for confounders^c^
Primary | Safe Dates Program | 2260 & 2261 | School | yes | no | yes | yes | no | yes
| Drug Abuse Resistance Education (DARE, DARE PLUS) | 9 | School | yes | no | yes | yes | yes | yes
| Student for Peace (Multi-component violence-prevention program) | 739 | School | no^d^ | no | yes | no | no | yes
| Students Management Anger and Resolution Together (SMART Talk) | 5246 | Team of students | no^d^ | no | yes | yes | no | yes
| Responding in Peaceful and Positive Ways - 7th grade (RIPP-7) | 5871 | Homeroom | no^d^ | no | yes | no | yes | yes
Secondary | Safe Dates Program | 2260 & 2261 | School | yes | no | yes | yes | no | yes
| Project Towards No Drug Abuse (TND) | 4315 | School | no^d^ | no | Not reported | no | no | yes
| Moving to Opportunity (MTO) demonstration project. | 10598 | Family | no^d^ | no | yes | Not reported | yes | yes
| Early community-based intervention for prevention of substance abuse and delinquent behavior | 6221 | Youth bureau | no^d^ | no | no | Not reported | no | yes
| Triple modality social learning program | 5995 | Subject | no^d^ | no | Not reported | yes | no | yes
| Childhaven's therapeutic child-care program (formerly Seattle Day Nursery) | 7158 | Subject | no | yes | yes | no | no | no
Tertiary | Turning Point: Rethinking Violence (TPRV) | 40 | Subject | yes | yes | Not reported | yes | yes^e^ | yes^f^
| Multi-systemic therapy (MST) | 2644 | Subject | no^d^ | no | yes | no | no | yes

a Criteria number 7 addressed whether all important outcomes were considered. Since we selected only articles with violence outcome, this criterion was common to all studies.

b If baseline characteristics were compared and found no differences, we considered “yes” for this criterion. If baseline characteristics were compared and found differences, we considered “no” for this criterion.

c Considered fatal flaws according to OMAR guideline.

d Significant baseline factors found between the two groups were adjusted in analysis.

e When all subjects were used in the analysis, intent-to-treat analysis was not necessary and a ‘yes’ was given to this criterion.

f Factors controlled by design.

Although all 13 studies are RCTs, only four randomized the subjects adequately. The other nine studies did not adequately randomize the subjects, as evidenced by significant baseline differences between the intervention and comparison groups. In eight of the nine studies that did not adequately randomize the subjects, the researchers adjusted for the differences in the final analysis. All but one of the 13 RCTs controlled for confounding factors in analysis. Only two of the 13 RCTs used blinding techniques for treatment assignment or for outcome assessment, reflecting the difficulty of blinding in behavioral studies. Intent-to-treat analysis was generally not performed; only four of the 13 RCTs used intent-to-treat analysis. Rate of follow-up of study subjects was not reported in two studies and was over 80 percent in six. The validity of instruments used to measure outcomes was reported in ten studies and was not reported in three. Only for one study was the instrument not considered valid.

Strictly speaking, none of the 13 RCTs fulfilled all six criteria enumerated here. If we excluded the randomization adequacy criterion, the blinding criterion, and the validity outcome criterion, and evaluated the quality based on the remaining three criteria — the 80 percent or greater follow-up rate, the use of intent-to-treat analysis, and the controlling of confounders in analysis, then two of the 13 RCTs fulfilled these three criteria. We do not believe that this system of evaluating study quality truly reflected the quality of the studies because the OMAR study quality criteria were derived primarily from clinical studies, and many of these criteria are not generally applicable to studies such as those considered in this analysis. The need to develop valid instruments to evaluate the quality of studies in the social sciences is apparent.