# Methods

## Development of the Project Team

We worked closely with the Director of the Southern California Evidence-Based Practice Center to assemble a team of clinical, behavioral, and methodological experts, most of whom were staff members and faculty at Childrens Hospital Los Angeles. The team included the Task Order Director, with overall responsibility for the project; the Task Order Manager and Synthesis Coordinator, a biostatistician responsible for the methodology of the review and with expertise in conducting evidence based reviews; the Task Order Coordinator, responsible for coordinating activities to ensure effective communication and reporting; four Task Order Literature Reviewers and Synthesizers from the fields of medicine (two pediatricians, one of whom is board certified in Adolescent Medicine) and public health; and a Librarian. Additional researchers, primarily masters and doctoral students from the fields of public health, psychology, and prevention research, joined the team for three months to assist with the primary and secondary reviews. During the first six months, the team met weekly to review and refine the methodology of the task order.

## Establishment of the Technical Expert Group (TEG)

In consultation with our Task Order Officer and the NIH Conference Panel Chair, we first created a Technical Expert Group (TEG) comprising nine individuals with both content and methodological expertise in the areas of youth violence and the prevention of youth violence. Specifically, we sought to create a multidisciplinary TEG that represented a range of related fields and disciplines, including early childhood development, adolescent development, juvenile justice, child abuse and neglect, anthropology, psychology, sociology, social work, public health, and public policy. The TEG was drawn from a large pool of potential candidates identified through a review of the literature and solicitation of nominations from researchers, and representatives from related federal agencies and private foundations. The list of potential technical experts and their curricula vitae were submitted to the Task Order Officer for approval. The final roster is provided in Appendix D1. *

* Appendices for this report are provided electronically at http://www.ahrq.gov/clinic/tp/adolvitp.htm.

## Defining the Scope of Key Questions

This study was guided by a set of specific research questions that were developed by an NIMH panel of experts and modified in the Task Order. The initial Task Order specified that the team review and examine evidence related to both youth violence and delinquency. The body of published research related to youth violence and violence prevention alone was believed to be massive. Thus, one of the first efforts was to review the scope of the evidence related to youth violence and violence prevention interventions and to delinquency and to refine the key research questions that guided the Task Order. To assess the feasibility of reviewing both sets of literature, we first conducted a preliminary search of relevant databases to obtain an estimate of the number of published articles that might potentially be reviewed. From this search, we learned that MEDLINE® alone contained over 6,000 citations related to youth violence and over 11,000 articles related to youth delinquency, with little overlap between these two bodies of literature. We then determined that given the project timeline and available resources, it would not be feasible to review the literature on youth violence as well as that on delinquency as outcome behaviors. Thus, in consultation with our Task Order Officer and the NIH Panel Chair, we limited the scope of this review to focus specifically on youth violence as an outcome. As a result, the key questions were modified to reflect the revised scope of this review. The following list of questions was used to inform the evidence review:

1. What are the factors that contribute to violence and associated adverse health outcomes in childhood and adolescence?
2. What are the patterns of co-occurrence of these factors?
3. What evidence exists on the safety and effectiveness of interventions for violence?
4. Where evidence of safety and effectiveness exists, are there other outcomes beyond reducing violence? If so, what is known about effectiveness by age, sex, and race/ethnicity?
5. What are the commonalties of the interventions that are effective, and those that are ineffective?
6. What are the priorities for future research?

## Development of Causal Pathways and Analytical Framework for Key Questions

Once the scope of the evidence report and the key questions were refined, we adopted definitions for youth violence and violence prevention interventions to further guide the selection and review of the appropriate literature. The definition of youth violence that we chose was developed by the Centers for Disease Control and Prevention Injury Center:

Violence is “the threatened or actual physical force or power initiated by an individual that results in, or has a high likelihood of resulting in, physical or psychological injury or death” (National Center for Injury Prevention and Control).

The definition of violence prevention interventions that we chose was developed for and published in the Surgeon General's Report on Youth Violence (Satcher, 2001): “Primary prevention interventions are those that are universal, intended to prevent the onset of violence and related risk factors; secondary prevention interventions are those implemented on a selected scale for children/youth at enhanced risk for youth violence, intended to prevent the onset and reduce the risk of violence; and tertiary prevention interventions are those that are targeted to youth who have already demonstrated violent or seriously delinquent behavior.”

We also generated a list of potential risk- and protective factors that have been found to be associated with youth violence. This list was, in turn, organized by domain – i.e., individual, family, school, peer, community, and social, and macro-level domains – and used to inform data abstraction and synthesis (Appendix E *).

Finally, we developed a framework to examine conceptually and analytically the associations between risk factors, violent behavior, and interventions. The Causal Pathways for Violent Behavioral Outcomes During Adolescence (Figure 1) focus on the age of exposure to risk factors. The Conceptual Framework for Risk and Protective Factors by Age of Exposure (Figure 2) depicts the potential opportunities for primary, secondary, and tertiary prevention of youth violence and associated adverse health outcomes.

Figure 1. Causal pathways for violent behavioral outcomes during adolescence

Figure 2. Conceptual framework for risk and protective factors by age of exposure

As these documents were being developed, we shared them with the NIH Panel Chair and our Task Order Officer. We also discussed these documents with members of our TEG during several teleconference meetings, and made numerous revisions based on the feedback that we received.

## Literature Search

As specified by the Task Order, the National Library of Medicine (NLM) performed all the searches that were used for this evidence review. Librarians from NLM met with project staff via teleconference to discuss the evidence review, the scope of the review, and the key questions. They also worked with project staff to select the literature databases that were ultimately used and evaluated the search strategies that had been developed by the project team.

In addition, members of the project team worked closely with the NIH Panel Chair and members of the TEG to decide how to further refine the scope of the review and hence, the search strategy. Decisions related to the scope of the review included determining which bodies of literature and search databases we would target and how far back in time we would search for related publications. Ultimately, we chose to limit our review to peer-reviewed published articles, articles retrievable within four search engines – MEDLINE®, PsychInfo, SocioAbstracts, and ERIC, and articles that were published in 1990 or thereafter, recognizing that by doing so, we would exclude a considerable segment of the literature. This decision was made in an effort to reduce the number of citations to be reviewed, given the time and resource constraints of the project and to ensure that our review was focused on the most current literature.

The decision was also made to limit the review to studies that were conducted in the United States, given growing evidence to suggest that numerous risk- and protective factors for violence are country specific, particularly factors that affect youth violence, and because the overarching purpose of the NIH consensus conferences will be to identify gaps and future research needs for research that will largely be conducted in the United States. Even with the limitations placed on the initial search for relevant literature, our first search generated over 10,000 unduplicated citations for review.

We chose to limit the scope of the review further to focus specifically on violent behavior perpetrated by youth, ages 12 through 17 years. We also did not include in our review the increasingly popular topics of verbal aggression, bullying, arson, weapon carrying, externalizing behaviors (e.g., acting out), attitudes about violent behavior, and intent to commit violence. Because our primary focus was on perpetration of violence, we also did not include the extensive literature about childhood and youth victimization. Moreover, this report does not review literature related to youth crime against property or materials (e.g. burglary, theft, vandalism). Thus, these related behaviors and attitudes are considered in this report only to the extent that they appear in the literature as risk factors for violence. In addition, the review did not include studies that examined precursors to violence that occurred in early adulthood (i.e., 18 years and older) or studies on the prevention of violence among young adults (i.e., 18 years of age and older).

As presented in Table 1, the NLM performed four searches in April/May of 2003 using four databases – MEDLINE®, PsychInfo, ERIC, and SocioAbstracts. The specific search strategies and terms used by NLM for these searches are provided in Appendices A1 through A9 *. Each time a search was performed, every effort was made to eliminate duplicate citations of articles that were referenced in more than one database.This process included an electronic removal of duplicate citations, first by NLM and then by the project librarian, followed by manual cross-checking of all citations.Table 1 provides a summary of the number of citations generated by each step and across the searches of the various databases provided to us by NLM.After elimination of duplicates, we were left with a total of 10,852 unique citations generated by these searches.A complete record of all titles and abstracts was kept using EndNote.We then performed a preliminary screening of these citations (described below).

Table 1 Citation counts for 2003 youth violence searches

Database | Search | Number of citations
MEDLINE | Search #1: April - Systematic Reviews | 1051
| Search #2: May - General Search | 3921
| Search #3: June - Revision | 982
| Search #4: July - Search for Direct, etc. | 16
| MEDLINE Total: | 5970
PsychINFO | Search #1: May - General Search | 3488
| Search #2: June - Revision | 479
| Search #3: July - Search for Direct, etc. | 2
| PsycINFO Total: | 3969
ERIC | Search #1: May - General Search | 495
| Search #2: June - Revision | 101
| Search #3: July - Search for Direct, etc. | 0
| ERIC Total: | 596
SocioAbstracts | Search #1: May - General Search | 183
| Search #2: June - Revision | 179
| Search #3: July - Search for Direct, etc. | 0
| SocAbs Total: | 362
| FINAL TOTAL: | 10,897*

* After internal elimination of duplicates, the net count was 10,852.

To ensure that articles published during the course of this project were included, the NLM conducted a second supplemental search in October of 2003, using the same search strategies and databases. This search yielded an additional 344 citations; thus a total of 11,196 citations were identified during the course of this project.

## Development of Data Collection Forms

We developed three data collection forms specifically for this project, including a Title/Abstract Screening Form (Form 1), a Secondary Screening Form for Full-Length Articles (Form 2), and the Study Quality Review Form (see Appendixes B1, B2, and B3 *).

The Title/Abstract Screening Form was developed as an initial screening tool to evaluate whether articles were appropriate for the evidence review, given the scope and key questions. The titles and abstracts (when available) were reviewed using six criteria to determine if they were eligible for inclusion within the evidence review. Articles were rejected if 1) they did not report original research findings (e.g., the article was an editorial, letter, discussion of clinical practice, overview, consensus statement, opinion piece, or commentary); 2) violence was not an outcome of the research; 3) the research did not involve human subjects; 4) the study was conducted outside the United States; 5) the age of the study population was 18 years or older; or 6) the study did not focus on youth as perpetrators of violence. If none of the rejection criteria applied, the article was deemed eligible for further review and the full-length article was retrieved.

The Secondary Screening Form of Full-Length Articles was developed to screen full-length articles for their appropriateness, given the scope and key questions. This form included three additional eligibility/rejection criteria, including 1) citation was a duplicate citation; 2) datawere not abstractable; and 3) study did not address one of the key questions. The form was also used to record the type of study design, using coded categories developed for and published in the Agency for Healthcare Research and Quality's Evidence Report Number 47: “Systems to Rate the Strength of Scientific Evidence” (West, King, 2002).

The Study Quality Review Form was used to evaluate the quality of each individual study; this form was adapted from guidelines that had previously been established by the OMAR to evaluate the quality of study designs (ODS and OMAR, 2003). The domains and elements for evaluating individual randomized controlled trials and observational studies are included in Form 3 (Appendix B3 *).

After developing these three screening/reviewing instruments, we conducted pilot testing and training with members of the project team to ensure the reliability and validity of the screening and review of data. For the primary screening, the entire team was given the same set of 10 titles and abstracts to review. The Task Order Manager and Coordinator then reviewed the results with the team to ensure that all reviewers were in agreement about criteria for rejection and inclusion. When discrepancies were identified or questions about key terms emerged, they were brought to the team for discussion and resolution. For the secondary review, the team was similarly trained. The Task Order Manager thoroughly reviewed the screening instrument and answered questions, particularly those regarding new reasons for rejection. Reviewers were instructed to submit questions to the Task Order Manager by email, and these questions were shared with the entire team and discussed at weekly meetings.

## Screening of Retrieved Titles/Abstracts Against Inclusion/Exclusion Criteria

When the searches had been completed and the duplicates had been removed, the citations were exported from EndNote into Microsoft Word so that each individual title and abstract could be printed on its own page for screening purposes. Excel spreadsheets were also created to record the results of the screening.

Two members of the team independently screened each citation. One screener was a member of the faculty with specific expertise related to adolescent development and/or youth violence, and the other screener had a masters degree in public health or was a doctoral student in the field of psychology, public health, or prevention research. The Task Order Manager or the Task Order Coordinator compared the screening results of the two screeners, resolved discrepancies, and recorded the decisions in the Excel master file. The citations for which full-length articles were to be pulled were forwarded to our librarian for retrieval. For the rejected citations, the reason for rejection was recorded (i.e., the first reason for rejection that was identified by the screeners). This protocol was followed throughout all screening processes.

Many citations identified through the initial and supplemental searches did not include an abstract or had a limited abstract. Thus, information was sometimes inadequate to perform the initial screening. In these cases, the full-length article was retrieved and the articles were screened using the secondary screening procedures (further described below).

At each staff meeting, the team reviewed the rules and instructions for screening and discussed any questions that arose during the initial round of screening. Most of the questions that arose during this round focused on whether or not terms used in the titles or abstracts corresponded to behaviors that fell within the definition of violence employed by the Task Order. These terms included, but were not limited to, conduct disorder, verbal aggression, oppositional defiant disorder, and externalizing behavior. Since many of these terms are not used uniformly in the literature and the title or abstract generally does not provide a full description of the behavior, many of these abstracts were accepted for further review.

## Retrieval and Review of Full-Length Articles

The titles/abstracts identified for further review were forwarded to the librarian for full article retrieval. Libraries at both Childrens Hospital Los Angeles and the Keck School of Medicine at the University of Southern California were the primary sources of the articles. Articles not found at either library were sought through Inter-Library Loan requests. We were able to retrieve all 1,612 full-length articles.

Two independent reviewers used the Secondary Screening Form to screen all the full-length articles; the same project staff and screening procedures used for the primary screening were used for the secondary screening. As with the title/abstract screening, the Task Order Manager compared the screening results provided by the two screeners, resolved discrepancies through consensus, and recorded the decisions on the Excel master file. This process resulted in one of two outcomes: The article was either accepted for data abstraction or rejected. As was done with the primary screening, the first reason for rejection identified by the two screeners was recorded for all rejected articles.

## Data Abstraction into Evidence Tables

For each article that was deemed eligible for inclusion, data were abstracted by a member of the project team and subsequently checked by the Task Order Manager. Two sets of evidence tables were constructed for this project: the Evidence Abstraction Table for Risk Factors (Evidence Table #1) which was specifically designed to address Key Questions #1 and #2, and the Evidence Abstraction Table for Interventions (Evidence Table #2) which was designed to address Key Questions #3–#5. The Task Order Manager presented drafts of the format, coding, and recording instructions for the two Evidence Tables to the team for comment and discussion. Based on this discussion, the Evidence Tables were modified prior to abstraction. The format for Evidence Table #1 and Evidence Table #2 are included in Appendixes B4 and B5 *.

To pilot test the forms, we assigned each reviewer the same two articles for abstraction: one article about risk factors and one about an intervention. As a result of this pilot testing, minor modifications were made to the abstraction forms. To ensure quality control over time, the team met regularly to discuss and review terms, procedures, and the abstraction process. In addition, reviewers submitted questions by email to the Task Order Manager, and the answers were shared with the entire review team. Most of the questions that arose during this period addressed missing data in the articles. For example, reviewers wanted to know whether or not to abstract an article when only the median age was provided (rather than the age range) and whether or not to abstract articles when the outcome reflected only attitudinal change or skill development but not a change in behavior. The Task Order Manager later checked all evidence tables for consistency and accuracy.

For the articles that addressed Key Questions #1 and #2, the following data were abstracted using the Evidence Abstraction Table for Risk Factors: 1) article identifier information, including internal record number, first author's last name, year of publication, and journal of publication; 2) characteristics of the study, including study design, study quality, sample size, age, gender and race or ethnicity description of the study population, time period, location, setting, study population, and inclusion and exclusion criteria; 3) risk factor information, including main independent risk factor(s), instrument(s) used to measure factors, and other factors studied; 4) outcome definitions and characteristics, including outcome measure(s), definition of the outcome, instrument used to measure outcome(s), type of instrument, circumstance or situational context in which the violence measured occurred, e.g. whether the violent incident was proactive or reactive, weapon used, and victim-offender relationship; 4) findings reported in the article; 5) any adverse health outcomes; and 6) whether the study was theory-driven and the theory that was used.

For the 32 articles that addressed Key Questions #3 through #5, the following data were abstracted using Evidence Abstraction Table for Interventions: 1) article identifier, including internal record number, first author's last name, year of publication, and journal of publication; 2) characteristics of the study, including study design, study quality, sample size, age, gender and race or ethnicity description of the study population, time period, location, setting, study population, and inclusion and exclusion criteria; 3) moderating and or mediating variables reported in articles; 4) outcome definition and characterization, including outcome measure(s), definition, instrument used to measure outcome, type, circumstance or situational context in which the violence measured occurred, e.g. whether the violent incident was proactive or reactive,, weapon used, and victim-offender relationship; 5) whether the program represented a primary, secondary, or tertiary intervention, the kind of intervention (such as behavioral, skill building, etc.), how the intervention was delivered, target population, setting where intervention was delivered, setting where subjects were recruited, professional background of the individual(s) performing intervention (e.g. teacher, psychologist, graduate student), duration of the program, and/or frequency of intervention; 6) study findings; 7) intervention effectiveness, and 8) any negative outcomes attributed to the intervention.

## Review and Assessment of Study Quality

For this Task Order, we were expected to use the criteria set forth in the Procedures for EPC Reports for Office of Dietary Supplements (ODS) and the Office of Medical Applications of Research (OMAR) (ODS and OMAR, 2003) to evaluate the quality of individual articles. Thus, to assess the quality of individual articles for Key Questions #1 and #2, we first evaluated the relevance of seven criteria previously developed for use with observational studies: 1) baseline comparability, 2) concurrent controls, 3) follow-up rate greater than or equal to 80 percent, 4) valid and reliable instruments used for assessments, 5) equal application of instruments for assessment, 6) important outcomes considered, and 7) appropriate control of confounders. Because all the prospective longitudinal cohort studies included in our review satisfied criteria #1, #2, #5, and #6 in the same ways, we used the three remaining criteria (i.e., #3, #4, and #7) to evaluate the quality of articles addressing risk and protective factors associated with youth violence. In addition, although it was not considered as a criterion, we examined the participation rate of each cohort study as well as the retention rate because we believe that it is important to maximize both the participation rate and follow-up rate to achieve an unbiased study sample for prospective longitudinal cohort studies. Large participation and retention rates are especially important for outcomes such as violence, because risk factors that are likely to contribute to youth violence are also likely to be associated with both participation and attrition rates.

For the Key Questions related to effectiveness of interventions, Key Questions #3, #4, and #5, we used the criteria set forth by OMAR for randomized controlled trials and observational studies (Appendix B3 *).The rating system used with randomized controlled trials consists of “Good”, “Fair” or “Poor.” A “Good” rating was assigned if the study fulfilled all the OMAR criteria without uncertainty, which means that comparable groups were assembled initially through adequately concealed randomization and maintained throughout the study (follow-up at least 80 percent) and an intention-to-treat analysis was used.Intention-to-treat analysis was performed for randomized controlled trials. Intention-to-treat is a strategy for analyzing data from randomized controlled trials that compares participants according to the groups towhich they were originally randomly assigned. This type of analysis is generallyinterpreted as including all originally enrolled participants in the final analysis, regardless of the treatment they actuallyreceived, whether they subsequently withdrew, or some other deviation from the protocol (Hulley, Cummings, 2001).A study was graded “fair” if any or all of the following problems occurred: the groups assembled initially were generally comparable but some questions remained whether some (although not major) differences occurred with follow-up due to differential attrition; some but not all important outcomes were considered; and some but not all potential confounders were accounted for.A “Poor” rating was assigned if the study failed to (at least partially) fulfill most criteria or if any of the following were reported: lack of comparability of groups assembled initially or failure to maintain them throughout the study; failure to mask outcome assessment; little or no attention given to key confounders; andlack of use of intent-to-treat analysis.. The rating system used with observational studies also used the “Good”, “Fair” or “Poor” categories. A “Good” rating was assigned when the following criteria were satisfied: 1) comparable groups were assembled initially and maintained throughout the study (follow-up at least 80 percent); 2) reliable and valid measurement instruments were used and applied equally to the groups; 3) all important outcomes were considered; and 4) appropriate attention was given to confounders in analysis.A study was rated as “fair” if any or all of the following problems occurred:1) generally comparable groups were assembled initially but some question remained whether some (although not major) differences occurred with follow-up, 2) measurement instruments were acceptable (although not the best) and generally applied equally, 3) some, but not all, important outcomes were considered, and 4) some, but not all, potential confounders were accounted for.A “Poor” rating was assigned if any of the following was reported: 1) groups assembled initially were not similar or comparable, or were not maintained throughout the study; 2) unreliable or invalid measurement instruments were used to assess exposure or outcomes or not applied equally among groups, and 3) key confounders were given little or no attention.

The rating system used with case-control studies also used the same three categories: “Good”, “Fair” and “Poor”. A “Good” rating was assigned when the following criteria were satisfied: 1) there was an appropriate ascertainment of cases and a nonbiased selection of case and control participants (i.e., cases and controls were drawn from the same population); the exclusion criteria were applied equally to cases and controls; 2) the response rate was equal to or greater than 80 percent; 3) diagnostic procedures and measurements were accurate and applied equally to cases and controls; and 4) appropriate attention was paid to confounding variables. A “Fair” rating was assigned for studies where: 1) there was no obvious subject recruitment or selection bias, 2) the retention rate was less than 80 percent, and 3) some attention was given to possible confounding variables. A “Poor” rating was assigned if: 1) significant sampling biases were evident, 2) the response rates were less than 50 percent, or 3) insufficient attention was given to important confounding variables.

## Procedures to Reduce Bias, Enhance Consistency, and Check Accuracy

To reduce selection bias, we assigned two reviewers — one faculty member with relevant expertise and one masters- or doctoral-level intern — to screen and review titles/abstracts and full-length articles at every stage of the selection process. For data abstraction, one member of the project team with at least a masters degree in public health, psychology, or prevention research abstracted the data onto evidence tables, and the Task Order Manager reviewed all of the evidence tables for data abstraction and recording accuracy.

## Analysis of the Scientific Evidence

We describe here our methods of data synthesis for the two sets of key questions: Questions #1 and #2, the risk factor questions; and Questions #3, #4, and #5, the intervention questions.

### Factors Contributing to Youth Violence (Key Questions #1 and #2)

Key Question #1 asks, “What are the factors that contribute to violence and associated adverse health outcomes in childhood and adolescence?” and Key Question #2 asks, “What are the patterns of co-occurrence of these factors?” where co-occurrence is defined as the simultaneous presence of two or more risk or protective factors that are predictive of violence in an individual.

We used the causal pathways depicted in Figure 1 and the conceptual framework laid out in Figure 2 to guide the design of our analytic framework for these two questions. In Figure 1, we indicated 32 pathways from birth through outcome assessment at ages 12 to17, broken down into 62 stage-paths or outcome-paths. A stage-path represents the path from one stage to another. An outcome-path represents the path from factor exposure to outcome within the same stage-path. In Figure 1, we used “A” to denote the exposure stage-path from the birth stage to the infant/toddler stage (age 0–3), “B” to denote the exposure stage-path from infant/toddler stage (age 0–3) to the early childhood/latency stage (age 4–8), “C” to denote the exposure stage-path from the early childhood/latency stage (age 4–8) to the early adolescent stage (age 9–11), D to denote the exposure stage-path from the early-adolescent stage (age 9–11) to the adolescent stage (age 12–17), and E to denote the exposure to outcome-path within the adolescent stage (age 12–17). A complete prospective longitudinal study would follow participants from birth to adolescence and would provide probabilities for each stage-path and outcome-path. Thus, a goal of our analytic framework was to estimate the probability for each stage-path and outcome-path as laid out in Figure 1. The probabilities derived for the 32 outcome-paths in stage E would provide us with the likelihood of violent behavior at ages 12 through 17 for the 32 causal pathways.

To address Key Questions #1 and #2, which were related to risk factors associated with youth violence, we chose to review and analyze only the published findings of studies that used a prospective longitudinal cohort study design to examine risk factors. The decision to do so was based on several factors. First, the longitudinal prospective cohort design has stronger internal validity than other designs such as retrospective cohort studies or cross-sectional studies. Second, cross-sectional studies would not allow us to scientifically identify temporal predictors of youth violence. Lastly, resource constraints would have made it difficult to analyze data from the 198 articles that reported findings from cross-sectional studies.

As previously noted, the primary outcome of interest was violence, defined as “threatened or actual physical force or power initiated by an individual that results in, or has a high likelihood of resulting in, physical or psychological injury or death” and, for this study, perpetrated by youth ages 12 through 17 years. This definition was further operationalized to include the following types of violent behavior during the adolescent years: murder or homicide, aggravated assault, non-aggravated assault, rape or sexual assault, robbery, gang fight, physical aggression, psychological injury or harm, and other serious injury or harm.

Categorization of Risk and Protective Factors. Risk and protective factors associated with the perpetration of violence were organized within five major domains: individual, family/home, peers, school, and community factors. Within each domain, we further organized the risk and protective factors into constructs, with a list of specific risk factors.

- Individual-level risk- and protective factors were divided into nine constructs: biological risk factors, race/ethnicity, physical development, neurological/cognitive development, psychological condition, school functioning, behavioral development, social ties, and life experience.
- Risk- and protective factors within the family/home domain included five constructs: home environment, family/parent characteristics, family conflict/harmony, parenting style or care-giver behaviors, and the quality of the parent-child relationship(s).
- Peer-related risk- and protective factors
- School-related risk- and protective factors included two constructs: the characteristics of the school environment and school policies.
- Community-level risk and protective factors also included two constructs: poverty/environmental risk factors and other environmental factors such as high crime rate, exposure to violent media, easy access to alcohol and drugs, easy access to firearms.

We developed this list of risk and protective factors following an initial review of the literature and then further expanded and/or modified it as we reviewed the evidence (Appendix E *).

Five age ranges/developmental stages were identified to further stratify the risk and protective factors by the timing of the exposure. These age ranges/developmental stages included prenatal exposure(prior to birth), infancy/toddler (0 through 3 years), childhood (4 through 8 years), early adolescence (9 through 11 years), and adolescence (12 through 17 years).

To examine the adverse health outcomes associated with the perpetration of youth violence, we established an additional classification scheme and coding system. The adverse health outcomes of youth perpetrators of violence were classified into five major categories: death, permanent and/or major physical disability, temporary and/or minor physical disability, mental health injury, and social health injury. Permanent and/or major physical disability included, but was not limited to, brain damage, paralysis, loss of extremities, and blindness. Temporary and/or minor physical disability included, but was not limited to, broken extremities. Mental health injuries included, but were not limited to, post-traumatic stress disorder (PTSD), depression, anxiety, and sexual problems. Social health injury included, but was not limited to, years of productive life lost, homelessness, family disruption, educational disruption, cycles of revenge and retaliation, STD/AIDS, and unintended pregnancy.

Grouping Data for Analysis. To search for homogeneous subgroups of participants for analysis, we stratified each of the studies included within the evidence review according to the following criteria:

- type of study population including gender, ethnicity, and risk level;
- characteristics of the study cohort including age at enrollment, duration of follow-up, and age at outcome assessment;
- type of outcomes being assessed; and
- type of analysis used to produce the findings.

We planned to pool findings from three or more studies within a homogeneous subgroup and provide pooled estimates of effect sizes. However, if we could not find three or more studies within a homogeneous subgroup for meta-analysis, we would use the vote-counting methods to summarize the study findings (Cooper and Hedges, 1994). Vote-counting is not the method of choice when test statistic values are reported for each study. Estimators based on vote-counting methods are less efficient than estimators based on effect sizes. Although vote-counting is not always the method of choice, in some cases we might not have a choice. If one or more of the studies do not report test statistics, but do report the direction and/or statistical significance of results, vote-counting procedures can be quite useful (Cooper and Hedges, 1994). In a vote-counting procedure, all studies that have data on a dependent variable and a specific independent variable of interest are examined. Three possible outcomes are defined. The relationship between the independent variable and the dependent variable is either significantly positive, significantly negative, or there is no specific relationship in either direction. The number of studies falling into each of these three categories is then simply tallied.

We summarized the study findings by the vote-counting procedure as follows:

- First, at least two cohort studies must report findings for a specific risk or protective factor. The evidence for a risk or protective factor was considered inadequate when it was reported in only one cohort study.
- Second, we classified the risk or protective factors into three categories of consistency:
  - ο those consistently reported as being significantly associated with violence (defined as at least 75 percent of the studies testing an association reporting a statistically significant result);
  - ο those consistently reported as being not statistically significantly associated with violence (similarly defined as ≥75 percent of studies); and
  - ο those where studies reported mixed findings.

A finding was considered to be statistically significant if the article reported a p-value less than 0.05. Because of the heterogeneity in the number and type of covariates or confounding factors included in the analytic model and the inconsistency in the way effect size was reported in the literature, we did not report the effect size of a study in the descriptive summary.

In many instances, study findings from a single cohort of subjects were reported in a number of articles. When this was the case, we used the cohort study as the unit of analysis rather than the article for either positive or negative outcome. Thus, in the summary of findings, different articles that reported the same outcomes for the same cohort were counted only once, whereas, findings for different outcomes were counted once for positive outcome and once for negative outcome. We also counted the same findings from different types of analysis within one article as one finding. When a finding was reported from both a bivariate analysis and a multivariate analysis in which the effects of other covariates were adjusted, only the finding from the multivariate analysis was used. To summarize the findings for each risk or protective factor, we included, first, the number of cohort studies that showed statistically significant findings, followed by the number of cohort studies that showed non-significant findings, both set off by parentheses. A finding that showed a p-value of less than 0.05 was considered statistically significant.

Sensitivity Analyses. This method of simply counting the number of studies with a significance positive or a significant negative finding is not recommended if it does not take into account the size and strength of the associations reported in the individual studies. In order to have a better understanding of the strength of the evidence on risk or protective factors reported this way, we conducted two sensitivity analyses to examine the risk or protective factors consistently reported to be associated or not associated with youth violence perpetration. The first sensitivity analysis considered the sample size and power of the study and the second sensitivity analysis considered the study quality.

For the sensitivity analysis on sample size and power, we used the thresholds set at a sample size of 1100 for the general population and 500 for the at-risk population. These thresholds were developed using the logistic regression model most used in the literature. Table 2 presents the power to detect a minimum odds ratio of 1.5 and 2.0 at a 0.05 level of significance for two levels of assumption regarding the correlation between the risk factor of interest and other risk factors in the model, various levels of probability of violence, and various cohort sizes, based on the logistic regression model. If we assume a 5-percent probability of youth violence at the mean level of the risk factors in the model for the low-risk population, a sample size of 1100 would be needed to achieve at least an 80 percent power to detect an odds ratio 1.5 or higher. If we assume a 15-percent probability of youth violence at the mean level of the risk factors in the model for the at-risk population, a sample size of 500 would be needed to achieve at least an 80 percent power to detect an odds ratio 1.5 or higher.

Table 2 Sample size and power considerations for logistic regression model

Probability at mean level of covariates | Sample size | Power to detect minimum odds ratio level
| | Odds ratio at 1.5 | | Odds ratio at 2.0
| | R=0.3 | R=0.5 | R=0.3 | R=0.5
Parameters in the Table:
1. Level of Significance at 0.05
2. Correlation of this covariate (R) with others in model at 0.3 and 0.5
3. Probability of violence at mean level of covariates at 0.15, 0.10, and 0.05.
4. Minimum detectable odds ratio at 1.5 and 2.0.
0.15 (for high-risk population) | 200 | 57% | 50% | 92% | 86%
| 300 | 72% | 65% | 98% | 96%
| 400 | 83% | 76% | 100% | 100%
| 500 | 90% | 84% | 100% | 100%
| 600 | 94% | 89% | 100% | 100%
| 700 | 96% | 93% | 100% | 100%
| 800 | 98% | 96% | 100% | 100%
| 900 | 99% | 97% | 100% | 100%
| 1000 | 100% | 98% | 100% | 100%
| 1100 | 100% | 99% | 100% | 100%
0.10 | 200 | 46% | 40% | 83% | 76%
| 300 | 60% | 53% | 95% | 90%
| 400 | 71% | 64% | 98% | 96%
| 500 | 80% | 73% | 100% | 99%
| 600 | 86% | 79% | 100% | 100%
| 700 | 90% | 85% | 100% | 100%
| 800 | 93% | 89% | 100% | 100%
| 900 | 96% | 92% | 100% | 100%
| 1000 | 97% | 94% | 100% | 100%
| 1100 | 98% | 96% | 100% | 100%
0.05 (for general population) | 200 | 30% | 27% | 62% | 54%
| 300 | 40% | 35% | 78% | 71%
| 400 | 49% | 43% | 88% | 82%
| 500 | 57% | 50% | 94% | 89%
| 600 | 64% | 57% | 97% | 94%
| 700 | 70% | 63% | 99% | 96%
| 800 | 76% | 68% | 99% | 98%
| 900 | 80% | 73% | 100% | 99%
| 1000 | 84% | 77% | 100% | 99%
| 1100 | 87% | 80% | 100% | 100%

In the second sensitivity analysis, we excluded the studies that did not meet all OMAR study quality criteria. We re-assessed the effect of heterogeneity by performing a sensitivity analysis on the subgroups of “good” quality studies, as defined by the OMAR criteria. As pointed out previously, while we initially intended to perform further sensitivity analysis by the size and strength of the association, this analysis was not possible because the size and strength of the association was often not reported and/or not abstractable.

It is important to note the difference in the analytic approaches necessary to answer Key Question #1 compared with Key Question #2. While Key Question #1 was intended to identify independent risk factors that have a high likelihood of leading to youth violence, Key Question #2 was intended to identify clusters of risk factors that may lead to youth violence. Very frequently, a factor that is found statistically significant in a univariate or bivariate analysis becomes non-significant after adjusting for other factors in the model. However, with Key Question #2, we are interested in identifying clusters of risk factors that occur simultaneously (termed co-occurrence here) and that lead to youth violence. Different from the independent factors identified in Key Question #1, the factors in a cluster are likely to be highly correlated and if we subject them to adjustment in multivariate analysis, many will likely become non-significant. Therefore, analytically, while we are looking for independent risk or protective factors that occur simultaneously in Key Question #1, we are looking for dependent or correlated risk or protective factors in Key Question #2.

### Interventions for Youth Violence (Key Questions #3, #4, and #5)

Key Question #3 asks, "What evidence exists on the safety and effectiveness of interventions for violence?

Key Question #4 asks, “Where evidence of safety and effectiveness exists, are there other outcomes beyond reducing violence? If so, what is known about effectiveness by age, sex, and race/ethnicity?”

Key Question #5 asks “What are commonalties of the interventions that are effective, and those that are ineffective?”

Our analytical plan for these questions included a process of stratifying studies and then pooling outcomes across a set of homogeneous studies.

The first step in our assessment was to stratify the accepted studies by the level of intervention and the type of study design. Initially we planned to stratify the studies by the various characteristics of an intervention, including the level of prevention (i.e., primary, secondary, tertiary), type of intervention (e.g., therapeutic, cognitive-behavioral), manner in which the intervention was delivered (e.g., one-on-one, small or large group), target population, setting where intervention was delivered (e.g., home, school, or community setting), setting from which subjects were recruited, type of professional performing the intervention (e.g., researcher, educator), and duration and/or frequency of intervention sessions. These important features of interventions might ultimately contribute to the effectiveness of an intervention. However, during our review, we found that many of the characteristics of the interventions were not described or reported in the literature. Thus, accepted studies were stratified only by the level of prevention and the study design.

An intervention was considered a primary prevention intervention when it was implemented universally, i.e., to prevent the onset of violence and related risk factors within the general population. A secondary prevention intervention was defined as an intervention that was implemented selectively with children/youth who had been identified as being at increased risk for violence, to prevent onset and/or reduce the risk of violence. Tertiary prevention interventions were defined as those interventions that were targeted to youth who had already engaged in violent behavior.

We stratified study designs into five types: randomized controlled trial, non-randomized controlled trial, prospective study, cross-sectional study, or single group time series study.

Within each stratum defined by level of intervention and study design, we further evaluated the homogeneity of the studies by the type of study population, type of outcome measures, and type of program. For the outcome measure of violence, we used the same criteria for stratification as for Key Questions #1 and #2. For the study population, we used the constructs and age brackets of the exposure factors to define the study population that received the intervention. Only published data were used (i.e., we did not contact authors for additional information). Study quality was not used as a criterion for stratification because of the lack of agreement about how to rate social science research.

Once the eligible studies were stratified according to these predefined criteria, we planned to use meta-analysis to pool the findings if three or more studies appeared in each homogeneous stratum. However, because of the heterogeneity of the study populations (age, gender, race/ethnicity, general or at-risk population), the characteristics of the programs (level, type, setting, duration/frequency), the outcome measures (rate of growth or decline, prevalence or incidence rate), and the measurement timeframes (before and after implementation; measures at one month, one year, or several years after intervention), no two programs were alike. Thus, we did not pool study findings using meta-analytic methods but summarized the findings qualitatively using the vote-counting methods instead.

## Rating the Strength of Scientific Evidence

According to the OMAR guidelines, EPCs are not required to make judgments about the overall strength of a body of evidence. The rating of the strength of scientific evidence remains the prerogative of the Consensus Panel. However, we conducted two sensitivity analyses to assist the Consensus Panel to assess the strength of the scientific evidence in our review. The first sensitivity analysis addressed the adequacy of number of subjects studied. We reanalyzed the data excluding the studies with sample size below the thresholds set at 1100 for the general population and 500 for the at-risk population. The second sensitivity analysis addressed the quality of studies. We re-assessed the findings excluding the studies that did not meet all OMAR study quality criteria.

## Priorities for Future Research (Key Question #6)

At the outset of the project, we established a conceptual framework (a road map of causal pathways); frameworks to categorize exposure factors, interventions, and violence outcomes; an analytical plan to assess the evidence according to key questions; and tools to assess study quality and rate the strength of the evidence. These items were used as yardsticks to measure the adequacy of the existing literature to address the key questions and to identify gaps in relevant research.

We used the findings from our rating of the overall strength of a body of evidence to identify gaps and potential areas for future research in three domains: quality, quantity, and consistency.

For quality, we addressed the extent to which the design, conduct, and analysis displayed by a body of research minimized selection-, measurement-, and confounding biases.

For quantity, we referred to the strength of the relationship between the exposure factor being evaluated and the outcome being measured, as well as to the amount of information supporting that relationship. Three main factors contributed to quantity: the magnitude of effect (i.e., estimated effects such as mean differences, odds ratio, relative risk, or other comparative measure); the number of studies performed on the topic in question (e.g., only a few versus perhaps a dozen or more); and the number of individuals studied, aggregated over all the relevant and comparable investigations, which provides the width of the confidence limits for the effect estimates.

For consistency, we referred to the degree to which a body of scientific evidence was in agreement with itself and with outside information. A body of evidence is said to be consistent when numerous studies performed in different populations using different study designs to measure the same relationship produce essentially similar or compatible results. In addition, consistency addresses whether a body of evidence agrees with externally available information about the topic. It is important to note, however, that consistency is not possible without a uniform approach to defining and operationalizing the independent and dependent variables studied.

While the first area of recommendations address the quality of the study, the second area of recommendations address the quality of the publication. We addressed the adequacy of description of the characteristics of the study such as study questions, conceptual framework, study design, description of study population, randomization procedures if any, blinding procedures, data collection procedures and instruments, validity of data collection instruments, definition of and rationale for choice of exposure factors and outcomes, analytical approaches, statistical analysis, and publication of findings.

The third area of recommendations addressed the methods we used to assess the evidence on this topic of youth violence. The criteria driving this evidence review have been effectively applied to a review of the literature relating to the treatment of illness and disease. However, we question whether these exact criteria and methods can be applied effectively in a review of research that examines such a complex social problem such as youth violence. We summarized what this evidence assessment has and has not contributed to the field and made suggestions of how future assessments of evidence could be approached.

It is our hope that this evidence report will provide a basis for future research not only in the area of youth violence, but also in the area of quality of research, quality of publications, and quality of evidence assessment methodology.

## Identification of Peer Reviewers

To identify a group of Peer Reviewers, we solicited nominations from our Technical Expert Group, our Panel Chair, and national associations recommended by our Project Officer (including the American Academy of Pediatrics, the American Public Health Association, the American Association of Health Plans, the American Academy of Family Physicians, the American Society of Internal Medicine, the American Psychological Association, and the American College of Physicians, and the Society of Adolescent Medicine). The role of Peer Reviewers is to provide independent feedback about the report. As a result of these solicitations, we received nominations for 24 individuals. These individuals represented federal agencies, academia, philanthropy, clinical practice, and managed care. From this list, the Task Order Project Director invited eight individuals — representing a variety of expertise and geography — to participate. This list of peer reviewers was approved by the Task Order Officer.

## Peer Review Process

A copy of the draft evidence report was mailed to each peer reviewer, along with an instruction sheet (Appendix B10 *) for reviewing the draft evidence report.A copy of the draft evidence report was also mailed to the members of the Technical Expert Group.All reviewers were asked to respond within three weeks. Six of the eight peer reviewers, six of the nine technical experts, and one AHRQ-appointed peer reviewer provided comments.Appendix D2 * lists the names and affiliations of the six peer reviewers who submitted their comments.

Upon receipt of all responses from the peer reviewers and technical experts, the project staff compiled a summary of the comments and changes and revised the draft evidence report accordingly. We submitted a complete copy of each reviewer's comments, together with the report of disposition of those comments to the Task Order Officer for review and approval.