# Appendix E: Coding system for risk factors

Level I | Level II | Level III | WHEN
Domain | Construct | Risk Factors | <0 | 0–3 | 4–8 | 9–11 | 12–17
77 | | | <0 | 0–3 | 4–8 | 9–11 | 12–17
0Individual | Biological | 1101=Male gender
| | 1102=In-utero exposure to alcohol, tobacco and drug (ATOD)
| | 1103=In-utero exposure to prescribed drug
| | 1104=In-utero exposure to lead
| | 1105=In-utero exposure to other environmental toxin, specify
| | 1106=Birth trauma/complication
| | 1107=age
| | 1108=sex hormone levels
| | 1188=other biological, specify
| | 1199=biological factor not specified
| Ethnicity | 1201=American Indian
| | 1202=Asian Pacific Islander
| | 1203=Black, Non Hispanic
| | 1204=Hispanic
| | 1205=White, Non Hispanic
| | 1288=other ethnicity, specify
| | 1299= Ethnicity not specified
| Physical Development | 1301=Minor physical anomalies
| | 1302=Small size
| | 1303=Dyssynchronous maturation
| | 1304=Early maturation
| | 1388=other physical development, specify
| | 1399=physical development factor not specified (somatic symptoms)
| Neurological/Cognitive Development | 1401=Head/brain injury
| | 1402=Epilepsy
| | 1403=Mental retardation
| | 1405=Low IQ
| | 1406=Poor motor-skill
| | 1407=Learning disability
| | 1408=Language disability
| | 1409=Attention deficit hyperactivity disorder/hyperactive/impulsive-attention deficit (HIA)
| | 1410=Low level of problem solving skills
| | 1411=Impulsivity
| | 1412=Emotion dysregulation
| | 1413=Aberrant social information processing
| | 1414=poor communication skills
| | 1488=other neurological development, specify
| | 1499=neurological factor not specified
| Psychological condition | 1501=Temperament, specify
| | 1502=Favorable attitude toward problem behavior
| | 1503=Depression
| | 1504=Bipolar disorder
| | 1505=Other affective disorder, specify
| | 1506=Schizophrenia
| | 1507=psychopathy
| | 1508=Suicidal ideation
| | 1509=Self-esteem/perceived life chances
| | 1510=destructive response to anger
| | 1588=other psychological condition, specify
| | 1588.1=mental health treatment
| | 1588.2=perceived risk of untimely death
| | 1588.3=poor perceived general health
| | 1588.4=fear of violence in school/home
| | 1588.5=perceived racism
| | 1588.6=emotional well-being
| | 1588.7=positive attitude toward problem behavior/lack of guilt/pro-violence attitude
| | 1599=psychological factor not specified
| School Functioning | 1601=Dropped out
| | 1602=Truancy
| | 1603=Misbehaving
| | 1604=Poor academic performance
| | 1605=repeating a grade
| | 1606=low school motivation/commitment
| | 1607=School transitions
| | 1688=other school functioning, specify
| | 1699=school functioning factor not specified
| Behavioral Development | [underlined: Antisocial behavior]
| | 1701=Alienation
| | 1702=Isolation/withdrawal
| | 1703=Lack of other interest/activities
| | 1708=other antisocial behavior, specify
| | 1709=antisocial behavior, unspecified
| | [underlined: Problem behavior]
| | 1711=Defiant/rebellious behavior, specify
| | 1712=High daring/Risk-taking propensity
| | 1713=Discipline problem at home/school
| | 1718=other problem behavior, specify
| | [underlined: Health related problem behavior]
| | 1721=Using drugs/alcohol
| | 1722=Early initiation of sexual activity
| | 1723=Pregnancy
| | 1724=Sexually transmitted infection
| | 1725=smoking
| | 1728=other health related problem, specify
| | [underlined: Aggressive behavior]
| | 1731=Verbal aggression
| | 1732=Physical aggression
| | 1733=Bullying
| | 1734=Animal abuse
| | 1738=other aggressive behavior, specify
| | [underlined: Delinquent behavior]
| | 1741=Truancy
| | 1742=Prostitution
| | 1743=Illicit drug use
| | 1744=Selling drugs
| | 1745=Carrying a weapon
| | 1746=Member of a gang
| | 1747=Criminal activity
| | 1748=other delinquent behavior, specify nonviolent felony offenses
| | 1749=delinquent behavior not specified
| | [underlined: Violent behavior]
| | 1751=Murder/homicide
| | 1752=Aggravated assault
| | 1753=Non-aggravated assault
| | 1754=Rape/sexual assault
| | 1755=Robbery
| | 1756=Gang fight
| | 1757=Fighting
| | 1758=Serious injury or harm to others
| | 1759=violent behavior, specify physical fight with same gender
| | 1798=early violence, not specified
| | 1799=behavioral developmental factor not specified
| Social Ties | [underlined: Peer Involvement]
| | 1801=Associate with antisocial peers
| | 1802=Associate with gangs
| | 1803=Associate with delinquent/violent peers
| | 1804=Rejected by conventional peers/peers disconnectedness
| | 1805=Peer victimization
| | 1806=Peer(s) drug use
| | 1807=Nonconventional peers
| | 1808=other peer involvement, specify
| | 1809=Bad friends, type not specified
| | [underlined: Other Involvement]
| | 1811=Lack of hobbies
| | 1812=Lack of religious belief and related activities
| | 1813=Lack of family commitments
| | 1814=Lack of school commitments and activities/school disconnectedness
| | 1815=Lack of community involvement
| | 1818=other involvement, specify
| | 1819=suicidal behavior of friends
| | 1820=same sex attraction
| | 1821=acceptance of prescribed social norms
| | 1822=negative sanctions
| | 1823=perceived normalcy
| | 1824=gender sterotyping
| | 1899=social ties factor not specified
| Life experience | 1901=Victim of abuse
| | 1902=Victim of domestic violence
| | 1903=Victim of community violence
| | 1904=Witness of domestic violence
| | 1905=Witness of community violence
| | 1906=High exposure to stressful events
| | 1907=Unemployment/employment
| | 1908=victim of violence not specified
| | 1909=death of parent(s)
| | 1988=other life experiences, specify
| | 1999=life experience factor not specified
FAMILY/ HOME | Home environment | 2101=Large family size
| | 2102=Overcrowding
| | 2103=Poverty/economic deprivation/low SES
| | 2104=Homelessness
| | 2105=Access to weapons/gun in homes
| | 2106=History of violence in home, specify
| | 2107=Exposure to violence in media
| | 2108=Relocation/high mobility
| | 2109=Lack of support network
| | 2110=Divorce/separation
| | 2111=Adoptive home
| | 2112=Foster home
| | 2188=other home environment, specify
| | 2199=home environment factor not specified
| Family/parents Characteristics | 2201=Single parent
| | 2202=Female head
| | 2203=Young parent(s)
| | 2204=Parent unemployment/unstable financial base
| | 2205=Low parental education
| | 2206=Low parental IQ
| | 2207=Inadequate problem-solving skills
| | 2208=Mental illness/parental depression or stress
| | 2209=Family criminal behavior
| | 2210=Antisocial parents (Parental social isolation)
| | 2211=Lack of spirituality/religiosity
| | 2212=Favorable attitudes concerning violence/crime and involvement in violence/crime
| | 2213=suicide behavior of family member
| | 2214=parent(s) drug use
| | 2215=mother's education
| | 2216=family beliefs
| | 2217=family structure
| | 2218=parental violence
| | 2219=poor family management
| | 2220=sibling delinquency
| | 2288=other family/parent characteristics, specify
| | 2299=family/parents factor not specified
| Family Harmony | 2301=Family conflict
| | 2302=Lack of communication
| | 2303=Immigrant/acculturation conflicts
| | 2304=Physical hitting between parents
| | 2305=Family cohesion
| | 2388=other family conflict, specify
| | 2399=family conflict not specified
| Care-Givers Treatment Toward Children | 2401=Child emotional abuse
| | 2402=Emotional neglect
| | 2403=Physical abuse
| | 2404=Physical neglect
| | 2405=Sexual abuse
| | 2488=Other child maltreatment, specified
| | 2499=caregiver's treatment factor not specified
| Parent-Child Relationship | 2501=Low parental supervision
| | 2502=Rejection by parent (negative attitude toward child)
| | 2503=Lack of parental involvement
| | 2504=Poor communication patterns
| | 2505=Harsh or inconsistent discipline
| | 2506=Neglectful parenting style
| | 2507=Overinvolved/overprotective parenting
| | 2508=Abnormal attachment style
| | 2509=Child lack of involvement
| | 2510=Positive interaction
| | 2511=Negative interaction
| | 2588=other parent-child relationship, specify
| | 2599=parent-child relationship factor not specified
SCHOOL | Characteristics | 3101=Located in poor area
| | 3102=High minority makeup
| | 3103=Low teacher to student ratio
| | 3104=High dropout rate
| | 3105=High absenteeism/truancy rate
| | 3106=High delinquency, violent, crime rate
| | 3107=Low academic performance - test score
| | 3108=Lack after-school programs
| | 3109=Lack parental involvement
| | 3188=other characteristic, specify
| | 3199=school characteristic not specified
| Policy | 3201=Low academic expectation
| | 3202=Tolerance of ATOD use
| | 3203=Tolerance of weapon/firearms
| | 3288=other policy, specify
| | 3299=school policy factor not specified
COMMUNITY | Poverty Environmental Stressors | 4101=High proportion on welfare
| | 4102=High level of unemployment
| | 4103=High density and overcrowding
| | 4104=Paucity of youth activities/programs
| | 4105=Social deprivation
| | 4106=Lack of community resources
| | 4107=High transient population
| | 4108=Community disorganization
| | 4109=Economic deprivation
| | 4110=Low neighborhood attachment
| | 4188=other poverty stressor, specify
| | 4199=poverty environmental stressor not specified
| Other Environmental Stressor | 4201=High levels of low birth weight infants
| | 4201=High crime rate
| | 4203=High minority population
| | 4204=High level of residential segregation
| | 4205=Pervasive gang activity
| | 4206=High level of crimes
| | 4207=High level of violence/violence exposure
| | 4208=Exposure to violent media
| | 4209=Exposure to youth-oriented advertising
| | 4210=Easy access to alcohol and drugs
| | 4211=Easy access to firearms
| | 4212=Absence of positive role model
| | 4213=Law enforcement against crime
| | 4288=other environmental stressor, specify
| | 4299=other environmental stressor not specified
MACRO-LEVEL ENVIRONMENT (POLITICAL REALITIES) | | 5001=Poverty/macrolevel economics
| | 5002=Racism
| | 5003=Sexism
| | 5004=Culture and history of violence
| | 5005=Capitalistic economy
| | 5006=Media glamorization of violence
| | 5007=Declining public support for families
| | 5008=Easy access to alcohol and drugs
| | 5009=Legal access to firearms
| | 5010=Ineffective youth laws/policies
| | 5011=Ineffective criminal justice system
| | 5012=Legitimacy of violent behavior
| | 5088=other macro stressor, specify
| | 5099=macro environmental factor not specified