# Appendix D: Technical Expert Group and Peer Reviewers

## Appendix D1: Technical Expert Group

Technical Expert | Affiliation/Location
Sonia Chessen | DHHS
| Washington DC
Sandra Graham, Ph.D | University of California
| Los Angeles, CA
Nancy Guerra, EdD | University of California
| Riverside, CA
Ron Haskins, PhD | Brookings Institute
| Washington, DC
Darnell Hawkins, JD, PhD | University of Illinois
| Chicago, IL
Doug Kirby, PhD | ETR Associates
| Scotts Valley, CA
Georgine Pion, PhD | Vanderbilt University
| Nashville, TN
Cathy Widom, PhD | New Jersey School of Medicine
| Newark, NJ
Franklin E. Zimring, JD | University of California
| Berkeley, CA

## Appendix D2: Peer reviewers

Peer Reviewer | Affiliation/Location
Paula M. Duncan, MD | Vermont Child Health Improvement Program
| Burlington, VT
Kathy Grasso, J.D. | US Dept.of Justice
| Washington, D.C.
Lynne Haverkos, MD, MPH | National Institute on Child Health & Human Development,
| Rockville, MD
Joan Sera Hoffman, PhD | Centers for Disease Control and Prevention
| Atlanta, Georgia
Patrick J. Kanary | Center for Innovative Practices
| Stark County Community Mental Health Board
Danielle Laraque, MD | Mount Sinai School of Medicine
| New York, NY