# Appendix C: Evidence Tables

## Appendix C1

Evidence Table 01. Risk Factors Contributing to Violent Behavior and Adverse Health Outcome

Record # | Study Quality | | Study Characteristic | Outcome (Violence) Definition and Characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | Risk Facros Studied | | Implications
| Sample Size | | Inclusion/Exclusion Criteria
5149 | [underlined: Study Design]: Prospective cohort study | | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Becker 2002 Am J Orthopsychiatry | [underlined: Study Quality Score:] Poor (retention rate 79%) | | Time 1: 1990 - 1991 | [underlined: Outcome measure] | To measure the direct effects of family violence and attention problems in childhood on violent behaviors at adolescence.
| [underlined: Sample size:] | | Time 2: 1996 - 1997 | Adolescent violent behavior measured at Time 2 | Time 1 predictors of violent behaviors among adolescent [underlined: boys] at Time 2:
| Original sample at Time 1: n=363 | | [underlined: Place (city, state)]: Unspecified | [underlined: Definition] | Risk Factor | Path Coefficient | p-value
| Total sample at Time 2: n=287 (79% of original) | | [underlined: Study Setting:] | •Threatened someone with a weapon | Marital Violence | ----- | NS
| Index group: n=141 | | Time 1: Research laboratories or shelters | • Hurt someone badly enough that they needed bandages/doctor | Paternal Abuse | ----- | NS
| Comparison group: n=146 | | Time 2: Research laboratories, shelters, or telephone | •Threatened to hurt people | Attention Problems | ----- | NS
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | | [underlined: Study Population:] | •Got in many fights | Conduct Problems | ----- | NS
| Age: | | Index group: Mother-child pairs who had been “abused by a partner in the past year” | •Physically attacked people | Age | 0.20 | >0.05
| Time 1: | Median = 9.3 yrs | Comparison group: Mother-child pairs who responded to an invitation to participate in a “University study of the family” | [underlined: Type:] Physical aggression | Violence-Nonviolence**
| | Range = 6–12 yrs | [underlined: Inclusion criteria:] Family must have one child between ages 6–12 living with the mother during the past year | [underlined: Instrument:] Self-reporting to 5 questions. | Correlation at time 2 | 0.58 | >0.05
| Time 2: | Range = 12–18 yrs | [underlined: Exclusion criteria:] | [underlined: Circumstance/Situational Context; Proactive/Reactive; Weapon used; Victim-offender relationship:] Unspecified | (Goodness-of-fit test, χ^2^(2, N=141) = 1.51; comparative fit index = 1.00)
| Gender: | | Children with: | [underlined: Adverse Health Outcome]: None reported | Time 1 predictors of violent behaviors among adolescent [underlined: girls] at Time 2:
| Male: | n=141 (49%) | • Various developmental disabilities | [underlined: Are mechanisms of violence theorized?] | Risk Factor | Path Coefficient | p-value
| Female: | n=146 (51%) | • Serious birth complications | Yes | Marital Violence | ----- | NS
| Race: | | • Prematurity | [underlined: If yes, state the theory:] “Cycle of violence” - exposure to family conflict at an early age, particularly child abuse or coercive parenting, underlie childhood conduct problems and adolescent delinquency | Paternal Abuse | 0.33 | >0.05
| Anglo-European | 53% | • Long-term chronic illnesses | | Attention Problems | ----- | NS
| Hispanic | 35% | [underlined: Main independent factor(s):] | | Conduct Problems | ----- | NS
| African American | 6% | • Marital violence (mother's reporting on Conflict Tactics Scale (CTS; Straus, 1979) | | Age | ----- | NS
| Native American, Asian, or Pacific Islander | 6% | • Paternal abuse (mother and child reporting) | | Violence-Nonviolence**
| | | • ADHD and Conduct Disorder (CD) (Mother reporting on Child Assessment Schedule (CAS) | | Correlation at time 2 | 0.54 | >0.05
| | | [underlined: Covariates:] | | (Goodness-of-fit test, χ2(2, N=145) = 3.31; comparative fit index = 0.99)
| | | • Age | | **nonviolent delinquency includes “snuck into house/building to steal something”, “hurt someone else's property”, “exchange money/drugs/food for sex”, “taken something worth less than $50”, “taken something worth more than $50”, “stolen a car”, “set fire to property”, “sold drugs to strangers”, and “sold drugs to friends”
| | | • Gender
Record # | Study Quality | Study Characteristic | Outcome (violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | Risk Factors Studied | | Implications
| Sample Size | Inclusion/Exclusion Criteria
1529 | [underlined: Study Design:] Prospective cohort study (Pittsburgh Youth Study) | [underlined: Study Period (begin, end):] Baseline: 1987 and 1988 Follow-up through 1993-1995. | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Beyers 2001 J Abnormal Child Psychology | - Oldest of 3 cohorts over 6.5 years, from age 13–19.5) | [underlined: Place (city, state):] Pittsburgh | [underlined: Outcome measure] | What are the predictors of repeated violence among male adolescents living in advantaged neighborhoods?
| [First 5 follow-up conducted every 6 months and subsequent 4 every 12 months.] | [underlined: Study Setting:] Advantage and disadvantaged neighborhoods | Repeated violent delinquency | Prevalence in % | Total Sample | High SES | Low SES
| [underlined: Study Quality Score:] Good | [underlined: Study Population:] Students with highest risk score based on # of antisocial or delinquent act from random samples of students provided by Education Board who participated in initial screening | [underlined: Definition] | Violent delinquency | 31.1 | 20.8 | 37.2
| [underlined: Sample size:] | [underlined: Inclusion criteria:] | Violent delinquency: | Repeated violent delinquency | 14.1 | 9.8 | 16.8
| Original: 506 | • Participated in at least 6 of 8 assessments subsequent to first follow-up assessment | 1) attacked another with a weapon or with the intent to seriously hurt or kill; | Official serious delinquency | 7.3 | 2.9 | 9.9
| Analysis: 420 (83%) | • Lived at address that permitted determination of neighborhood membership at first assessment | 2) used a weapon, force or strong arm method to get something from someone; | [underlined: Unadjusted Odds Ratio (95% CI)]
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | [underlined: Exclusion criteria:] Engaged in repeated violence before second follow-up assessment | 3) physically hurt or threatened to hurt someone to get them to have sex and | | High SES (159) | Low SES (261)
| [underlined: Age] | [underlined: Main independent factor(s):] Neighborhood SES | 4) had sex with someone against their will. | [underlined: Demographic]
| 13–19.5 y, 13 years old at time of initial assessment | [underlined: Other risk factors] | Must be endorsed by youth or by teacher regarding youth. | Older Age | 0.97 (0.46,2.06) | 1.88 (1.24,2.84)
| [underlined: Gender:] all males | A total of 19 predictors in four domains: Demographic, individual, family and peer. [See Findings column for list]: | Repeated violence: if one of these items was endorsed on two or more interviewing phases. | Race/Ethnicity | 2.14 (0.69,6.63) | 1.92 (0.74,5.04)
| [underlined: Race] | [underlined: Instruments]: Several sources: Neighborhood SES based on 1990 U.S. Census; Achenbach Child Behavior Checklis; Self-Reported Delinquency Scale, and Denver High Risk Delinquency Survey. | [underlined: Instruments]: SRD (Elliott) and TRF (Archenbach) | Single parent status | 1.00 (0.35,2.89) | 1.41 (0.71,2.84)
| African American 57% | | [underlined: Type:] see definition | Family SES | 0.94 (0.90,0.97) | 0.74 (0.72,0.76)
| | | [underlined: Circumstance/Situational Context:] see definition | [underlined: Individual]
| | | [underlined: Proactive/Reactive] | Physical aggression | 3.09 (2.09,4.56) | 1.49 (1.22,1.82)
| | | Not explicitly stated, but proactive by implication | Impulsive/Hyperactive | 4.68 (3.40,6.44) | 1.61 (1.43,1.81)
| | | [underlined: Weapon used:] Not specified | Low academic achievement | 1.75 (0.79,3.89) | 1.47 (0.85,2.54)
| | | [underlined: Victim-offender relationship] | Low school motivation | 2.03 (1.37,3.02) | 1.98 (1.53,2.56)
| | | Not stated. | Pos attitude to problem beh | 2.19 (1.97,2.44) | 1.89(1.77,2.03)
| | | [underlined: Adverse Health Outcome]: Not studied | Lack of guilt | 2.33 (1.74,3.12) | 1.80 (1.53,2.12)
| | | [underlined: Are mechanisms of violence theorized?] | Had sex (<13.5y) | 3.70 (1.26,10.9) | 5.69 (2.47,13.1)
| | | Yes. The [underlined: Bioecological model (Bronfenbrenner et al)] | Carried hidden weapon | 2.42 (0.82,7.13) | 3.77 (1.83,7.78)
| | | | [underlined: Family]
| | | | Low communication | 1.16 (1.09,1.22) | 1.72 (1.66,1.79)
| | | | Boy not involved | 1.72 (1.30,2.28) | 1.56 (1.32,1.86)
| | | | Discipline not persistent | 1.10 (0.75,1.62) | 1.05 (0.86,1.28)
| | | | Poor supervision | 0.90 (0.58,1.39) | 1.43 (1.17,1.73)
| | | | [underlined: Peer]
| | | | Peer delinquency | 4.43 (1.42,13.8) | 2.94 (1.48,5.85)
| | | | Nonconventional peers | 0.80 (0.73,0.88) | 1.03 (0.97,1.10)
| | | | Bad friends | 1.41 (1.06,1.86) | 1.58 (1.32,1.88)
| | | | [underlined: Adjusted Odds Ratio for significant factors]
| | | | Physical aggression | 3.09
| | | | Lack of guilt | | 1.53
| | | | Had sex | | 3.94
| | | | Carried hidden weapon | | 2.50
| | | | Poor communication | | 1.57
Record # | Study Quality | | | Study Characteristic | Outcome (Violence) Definition and characterization | Findings
Author Year, Jnl | Group(s) Demographics | | | Risk Factors Studied | | Implications
| Sample size | | | Inclusion/Exclusion Criteria
37 | [underlined: Study Design:] Prospective cohort study (ADD Health - a national study of adolescents in grades 7–12). | | | [underlined: Time (begin, end):] | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Borowsky 2002 Ambulatory Pediatrics | [underlined: Individual study quality score] | | | Time 1 interview: Apr-Dec 95 | [underlined: Outcome 1:] | 1) To compare violence perpetration between youth who have and have not reported a history of repeating a grade by gender*
| Poor (attrition > 20%) | | | Time 2 interview: Apr-Aug 96 | [underlined: Violence perpetration] | Repeat a grade | | | | Yes | No | Yes | No
| [underlined: Sample size (initial and actual):] | | | [underlined: Place (city, state):] US | [underlined: Measure]: 8 items (see list Findings), equally weighted, reflecting serious interpersonal violence perpetration within the past 12 months. Scale was dichotomized at the 80th percentile. | Outcome | | | | Girls | Girls | Boys | Boys
| Completed Time 1 interviews: 20,745 (77% of invited to participate) | | | [underlined: Study Population:] | [underlined: Type]: See list of outcome measures in Findings | Got into serious fight | | | | 20.6 | 13.3 | 33.2 | 25.5
| Completed Time 2 interviews: 14,738 (71%) | | | •Analysis 1: Adolescents in grades 7–12 | [underlined: Instruments Used:] Not specified | Participation in group fight | | | | 19.9 | 13.7 | 31.1 | 21.0
| Completed Time 1 & 2: 13,781 (66%) | | | •Analysis 2: Adolescents repeating a grade | [underlined: Circumstance, Proactive/reactive, Victim-offender relationship]: Not specified | Hurt someone badly enough to require bandages or medical care | | | | 6.8 | 4.4 | 17.5 | 11.5
| Analysis: 11,781 (57%) | | | [underlined: Inclusion criteria:] Not specified | [underlined: Weapon used:] See measures | Fighting that resulted in personal Injury requiring medical care | | | | 4.7 | 2.5 | 9.5 | 4.3
| Index group defined as those with history of grade retention: 3,265 | | | [underlined: Exclusion criteria:] Not specified | [underlined: Adverse Health Outcome]: Not studied | Use or threatened use of a weapon | | | | 5.6 | 1.8 | 7.1 | 3.9
| [underlined: Subjects in analysis 1:] Total: 11,781 (57%) | | | [underlined: Main independent factor(s):] History of grade retention | [underlined: Are mechanisms of violence theorized?] | Pulled a knife or gun on someone | | | | 5.0 | 1.9 | 12.9 | 5.4
| | Repeated a grade | | [underlined: Risk/Protective Factors] | Yes. A risk and resiliency framework which proposes that vulnerability to health-jeopardizing outcomes among youth is affected by the number and nature of life stressors as well as the presence of protective factors that buffer the impact of these stressors. | Use of weapon in fight | | | | 3.2 | 1.4 | 8.5 | 3.8
| | Yes | No | Community characteristics: | | Shot or stabbed someone | | | | 1.4** | 0.7 | 5.7 | 2.0
| Girls | 1374 | 3607 | •Fear of violence in school or neighborhood, | | *p<.001 for all comparisons except as noted
| Boys | 1891 | 4909 | • peer suicide involvement, | | **p=.01
| [underlined: Subjects in analysis 2:] | | | •perceived racism, | | 2) To identify risk factors for Time 2 violence perpetration among youth who have repeated a grade
| Total: 3,265 | | | •connectedness with school | | | | | | [underlined: Odds Ratios (95% CI)]
| Girls | 1374 | | Family factors: | | Risk Factors | | | | Girls | | Boys
| Male: | 1891 | | •Parent-family relationships, | | [underlined: Community context]
| [underlined: Ethnicity/Race]: not reported | | | •parental expectations for adolescent behavior, | | Suicidal behavior of friend | | | | 2.16 (1.45–3.21) ^c^ | | 1.80 (1.29–2.50) ^c^
| | | | •parental modeling, and | | [underlined: Family context]
| | | | •household features | | Suicide behav of family member | | | | 1.02 (0.59–1.76) | | 2.06 (1.28–3.31) b
| | | | Individual characteristics: | | Gun in home | | | | 1.30 (0.71–2.37) | | 1.37 (1.00–1.90) ^a^
| | | | •Academic performance, | | [underlined: Individual characteristics]
| | | | •violence-related behaviors, | | Suicide attempt | | | | 3.23 (1.86–5.59) ^c^ | | 1.67 (0.92–3.03)
| | | | •substance use | | Mental health treatment | | | | 2.00 (1.41–2.84) ^c^ | | 1.53 (1.06–2.23) ^a^
| | | | •employment, | | Perceived risk of untimely death | | | | 1.19 (0.91–1.56) | | 1.47 (1.20–1.79) ^c^
| | | | •Emotional well-being, | | Somatic symptoms | | | | 2.17 (1.18–3.99) ^a^ | | 2.65 (1.53–4.58)
| : | | | •health status, | | Poor perceived general health | | | | 2.36 (1.14–4.87) a | | 2.16 (1.27–3.66) b
| | | | •perceived risk of premature mortality, and | | Same sex attraction | | | | 1.20 (0.58–2.46) | | 2.05 (1.29–3.26) ^b^
| | | | •religious identity | | School problems | | | | 4.49 (2.42–8.34) ^c^ | | 3.08 (1.91–4.95) ^c^
| | | | | | Skipping school | | | | 2.23 (1.19–4.20) a | | 2.63 (1.77–3.91) c
| | | | | | Violence victimization | | | | 3.49 (2.31–5.28) ^c^ | | 3.79 (2.90–4.94) ^c^
| | | | | | Weapon carrying | | | | 3.60 (2.20–5.89) ^c^ | | 3.24 (2.38–4.24) ^c^
| | | | | | Violence perpetration at Time 1 | | | | 5.77 (3.98–8.35) ^c^ | | 4.72 (3.72–6.01) ^c^
| | | | | | Alcohol use | | | | 7.17 (3.81–13.5) ^c^ | | 4 91 (3.00–8.07) ^c^
| | | | | | Marijuana use | | | | 3.53 (1.88–6.61) ^c^ | | 3.45 (2.25–5.28) ^c^
| | | | | | Other illicit drug use | | | | 2.18 (1.33–3.58) ^b^ | | 2.90 (1.96–4.28) ^c^
| | | | | | 3) To identify protective factors for Time 2 violence perpetration among youth who have repeated a grade (adjusted for age, race/ethnicity, family structure, and welfare status)
| | | | | | | | | | Adjusted Odds Ratios (95% CI)
| | | | | | Risk Factors | | | | Girls | | Boys
| | | | | | [underlined: Community context]
| | | | | | Adult caring | | | | 0.46(0.20–1.09) | | 0.45(0.26–0.76) ^b^
| | | | | | School connectedness | | | | 0.29(0.15–0.56) ^c^ | | 0.44(0.27–0.70) ^c^
| | | | | | School safety | | | | 0.50(0.27–0.93) ^a^ | | 0.78(0.49–1.24)
| | | | | | [underlined: Family context]
| | | | | | Parental presence | | | | 0.72(0.35–1.50) | | 0.49(0.27–0.89) ^a^
| | | | | | Parent-family connectedness | | | | 0.36(0.21–0.62) ^c^ | | 0.33(0.20–0.54) ^c^
| | | | | | Parental school expectations | | | | 1.51(0.86–2.65) | | 0.48(0.32–0.73) ^c^
| | | | | | [underlined: Individual characteristics]
| | | | | | Emotional well-being | | | | 0.36(0.20–0.64) ^c^ | | 0.51(0.30–0.85) ^b^
| | | | | | Grade point average | | | | 0.36(0.15–0.91) ^a^ | | 0.23(0.13–0.41) ^c^
| | | | | | ^a^ p<0.05; ^b^ p<0.01; ^c^ p<0.001
| | | | | | 4) Predicted probabilities that an adolescent who has repeated a grade will be in top quantile of violent behavior
| | | | | | | | | | Girls | Girls | Boys | Boys
| | | | | | P(N) | P(A) | P(B) | P(C) | R(H) | R(L) | R(H) | R(L)
| | | | | | 0 | 0 | 0 | 0 | 56.7 | 12.3 | 52.4 | 23.8
| | | | | | 1 | 1 | 0 | 0 | 54.9 | 11.5 | 49.9 | 22.0
| | | | | | 1 | 0 | 1 | 0 | 54.2 | 11.3 | 47.6 | 20.4
| | | | | | 1 | 0 | 0 | 1 | 48.7 | 9.2 | 35.3 | 13.4
| | | | | | 2 | 1 | 1 | 0 | 52.4 | 10.6 | 45.0 | 18.8
| | | | | | 2 | 1 | 0 | 1 | 46.9 | 8.7 | 33.0 | 12.2
| | | | | | 2 | 0 | 1 | 1 | 46.2 | 8.4 | 31.0 | 11.3
| | | | | | 3 | 1 | 1 | 1 | 44.4 | 7.9 | 28.9 | 10.3
| | | | | | P(N): number of protective factors
| | | | | | P(A): Protective factor A - parent-family connectedness
| | | | | | P(B): Protective factor B - school connectedness/parental presence
| | | | | | P(C): Protective factor C - grade point average
| | | | | | R(H): High in all 3 risk factors:
| | | | | | violence victimization or perpetration,
| | | | | | substance use
| | | | | | school problems
| | | | | | R(L): Low in all 3 risk factors.
Record# | Study Quality | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | Risk Factors Studied | | Implications
| Sample Size | Inclusion/Exclusion Criteria
5303 | [underlined: Study Design]: Prospective cohort study (Youth in Transition (YIT) survey, initiated in 1966 by the University of Michigan) | [underlined: Study Period (begin, end):] 1966-1967 | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Brezina.1999 Youth & Society | [underlined: Study Quality Score:] | [underlined: Place (city, state):] Nationwide sample of male public high school students clustered in 87 schools. | [underlined: Outcome measure] | This study tests the reciprocal relationship between parental and child aggression, characterized by countervailing effects. Two models of reciprocity: A) cross-lagged, i.e.,parental aggression at T1 is assumed to have a lagged effect on child aggression in T2 and child aggression in Time 1 is assumed to have a lagged effect (negative/deterrent) on parental aggression in T2. B) contemporaneous, i.e., reciprocal effects are simultaneous, concurrent or occur in proximate time. The current level of aggression toward the child is likely to stimulate immediate reactive aggression toward the parents.
| Good if only retention rate is considered (85%) | [underlined: Study Setting]: School | Child Aggression toward parents | Independent variables | Model A Aggression 2 | | Model B Aggression 2
| Poor if retention rate and % used in analysis are considered (69%) | [underlined: Study Population:] Sample obtained from first and second waves of Youth in Transition Study (1966) at the Insitute for Social Research, Univ. of Michigan (Bachman, O'Malley & Johnson, 1978) | Parental aggression toward child | | Parental | Child | Parental | Child
| [underlined: Sample size]: | [underlined: Inclusion criteria]: Male, 10^th^ grade, but otherwise unspecified | [underlined: Definition] | Parental aggression 1 | .49(.03)* | .20(.03)* | .53(.03)* | --------
| Wave 1: N =2213 | [underlined: Exclusion criteria]: Female, but otherwise unspecified | •.# times a) hit their mother and b) hit their father (past 3 years, W1, past 1.5 years W2). | Child aggression 1 | -.08(.03)* | .46(.03)* | --------- | 49(.03)*
| Wave 2: N =1883 (85%) | [underlined: Main independent factor(s):] Parental Aggression | •.Measured in a Likert scale: 1 (never) to 5 (always) | Parental aggression 2 | --------- | --------- | --------- | .40(.07)*
| Analysis: N=1519 (69%) | [underlined: Instrument used to measure factors:] Self-report: How often do your parents actually slap you? (likert scale: 1 (never) to 5 (always) | •.2-item scale created to index overall level of child-to-parent assault. | Child aggression 2 | --------- | --------- | -.19(.06)* | --------
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | [underlined: Other independent factors:] | •.Mean of these items constitutes scale score | Socio-economic status | -.07(.03) | .03(.02) | -.06(.03) | .06(.02)
| Age: | •SES | [underlined: Instrument used to measure outcome] | Race | -.10(.04) | .26(.02)* | -.06(.03) | .30(.03)*
| Wave 1: 10th grade boys (beginning of year, modal age: 15 years) | •Parental attachment (Parental Attachment Scale) | Child's self-report | Parental attachment | -.04(.03) | -.13(.02)* | -.07(.03) | -.11(.02)*
| Wave 2: 11^th^ grade boys (completion of year, age unspecified) | •.Attitude toward aggression (Approval of Aggression Scale) | [underlined: Type] | Approval of aggression | -------- | .08(.02)* | -------- | .08(.02)*
| Gender: Boys only | •.Parents' mean age | Physical aggression toward parent | Parents' age | -.06(.02)* | .06(.02)* | -.05(.02) | .08(.02)*
| Race: unspecified | •.Physical size-respondent | [underlined: Circumstance/Situational Context] | Physical size-respondent | -.02(.02) | .02(.01) | -.01(.02) | .02(.02)
| | •.Race (white/non-white | Child-to-parent in response to parent-to-child aggression | R**2 | .17 | .36 | .25 | .37
| | | [underlined: Proactive/Reactive] | [underlined: Are mechanisms of violence theorized?]
| | | Hypothesized to be reactive | Yes, Strain Theory, Social Learning Theory, and Coercion Theory.
| | | [underlined: Weapon used] | Consistent with theorectical accounts, the results indicate a reciprocal relationship between parental and child aggression, characterized by countervailing effects. Although aggression by parents (slapping) tends to foster aggression on the part of the male adolescent child, aggression by the male adolescent child tends to deter the assaultive behavior of parents.
| | | Hitting
| | | [underlined: Victim-offender relationship]
| | | Family
Record # | Study Quality | Study Characteristic | Outcome (violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | Risk Factors Studied | | Implications
| Sample Size | Inclusion/Exclusion Criteria
5689 | [underlined: Study Design]: Prospective cohort study (Oregon Youth Study) | [underlined: Study Period (begin, end):] 1983 - 1992 | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Dishion 1997 Social Develop-ment | [underlined: Study Quality Score:] | [underlined: Place (city, state):] Medium-sized metropolitan region of the Pacific Northwest | [underlined: Outcome measure] | With infrequent violence reported during adolescence, a wave by wave growth model was difficult to model. Instead, indicators of violence (self report and juvenile records) were aggregated throughout adolescence and analyzed using multiple regression procedures.
| Good if only retention rate is considered. | [underlined: Study Setting]: School | Number of violent acts committed in past year | [underlined: Correlations between constructs (N=195)]
| Poor if both participation and retention rates are considered. | [underlined: Study Population:] At-risk boys, their parents and friends, sampled from public schools in higher juvenile crime neighborhoods. | [underlined: Definition] | Construct | 1 | 2 | 3 | 4 | 5
| [underlined: Sample size]: | [underlined: Inclusion criteria]: 4th grade boys | Self report: Assault, robbery and rape. | 1. Parental discipline | 1.00
| N=206 (of 277 eligible) | [underlined: Exclusion criteria]: Female | Arrest: assault, menacing, robbery, rape. | 2. Child antisocial | -.65*** | 1.00
| Cohort 1: '83–84 (n=102) | [underlined: Main independent factor(s) and instruments used:] | [underlined: Instrument used to measure outcome] | 3. Peer deviancy training | -.19** | .42*** | 1.00
| Cohort 2: '84–85 (n=104) | • Antisocial behavior (Child-interview; parent and teacher: CBC-L Externalizing (Achenbach) | Child's self-report (Elliot's delinquency interview, 1983) | 4. Self-report violence | -.21** | .51*** | .32*** | 1.00
| Analysis: 195 (95%) | • Parental Discipline (Family Process Code for nattering and abusive cluster and Discipline questionnaire) | Juvenile court records from county of residence - all police contacts, excluding child neglect or abuse | 5. Arrest violence | -.29*** | .34*** | .32*** | .21** | 1.00
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | • Deviancy training (Topic Code rule- breaking talk and Dyad Violence questionnaire) | [underlined: Type:] see above | Note: * p <.05 ; ** p <.01; *** p <.001
| Age: | | [underlined: Circumstance/Situational Context] | Multiple regression analyses for Self-reported violence (n=194):
| Wave 1: 9–10 years | | Except gang-related violence, not specified | | | β | t | p
| Wave 2: 11–12 years | | [underlined: Proactive/Reactive] | Childhood antisocial behavior | | 0.44 | 5.59 | <0.001
| Wave 3: 13–14 years | | Not specified | Parental discipline in childhood | | 0.11 | n/r | ns
| Wave 4: 15–16 years | | [underlined: Weapon used] | Deviancy training | | 0.29 | 4.48 | <0.01
| Wave 5: 17–18 years | | Not specified | Model R**2 is 0.32, F=31.02, p<0.001.
| Gender: Boys only | | [underlined: Victim-offender relationship] | Logistic regression analyses for Police contacts for violence offense (n=194):
| Race: “predominently white” | | Peer and other unspecified | | | β | Wald | p
| | | [underlined: Adverse Health Outcome]: None | Childhood antisocial behavior | | 0.48 | 3.16 | <0.10
| | | [underlined: Are mechanisms of violence theorized?] | Parental discipline in childhood | | -0.48 | 3.55 | <0.10
| | | Yes | Deviancy training | | 0.78 | 11.2 | <0.01
| | | [underlined: If yes, state the theory:] Coercion Model of Antisocial Behavior | The odds ratio for Arrest was 2.14, corresponding to a probability of 0.76. Thus controlling for the influence of earlier levels of both child antisocial behavior and parental discipline practices, boys who engage in deviancy training with friends tended to have a high probability of being arrested for a violent act than those whose friendships were based on normative topics.
Record# | Study Quality | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | Risk Factors Studied | | Implications
| Sample Size | Inclusion/Exclusion Criteria
5704 | [underlined: Study Design]: Prospective cohort study (ADD Health- the National Longitudinal Study of Adolescent Health) | [underlined: Study Period (begin, end):] 1995-1996 | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Dornbusch 1999 Intl J Adolesc Medicine and Health | [underlined: Study Quality] | [underlined: Place (city, state):] U.S.A. | [underlined: Outcome measure] | To study the effects of the use of 6 types of substances on the longitudinal change in adolescent violence.
| [underlined: Score: Poor] (attrition believed to be >20%) | [underlined: Study Setting:] School-based | Violent behavior at Time 2 | Multivariate Regression-Baseline Model 1:
| [underlined: Sample size]: 13568 [n used in the analysis not reported. However, Figure 2 gave an n=9,233 in the cross-lagged model. The question is raised as to whether 9,233 cases were used in all analyses] | [underlined: Study Population:] A nationally representative sample of 7^th^–12^th^ grade students in the U.S., surveyed in Waves I and II of the National Longitudinal Study of Adolescent Health, 1994-1996 | [underlined: Definition] | | [underlined: Time 2 violence]
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | [underlined: Inclusion criteria:] All adolescents who participated in both Wave I (1995) and Wave II (1996) in-home data collection, and for whom sample weights were available. | Any of the following in the preceding 12 months: | | [underlined: Everyone] | | | [underlined: Male] | | [underlined: Female]
| Age: Not specified | [underlined: Exclusion criteria]: None | • pulled knife/gun | R^2^ | 0.277 | | | 0.239 | | 0.318
| Gender: Not specified | [underlined: Main independent factor(s):] | • shot/stabbed someone | [underlined: Factor] | [underlined: Coeff.] | | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value] | [underlined: Coeff]. | [underlined: p-value]
| Race: Not specified | • Cigarette smoking | • in a serious physical fight | Female gender | -0.014 | | <0.001
| | • Alcohol use | • used a weapon in a fight | Age | -0.002 | | <0.05 | -0.001 | ns | -0.003 | <0.001
| | • Marijuana | • victim needed bandages or medical care | Parent education | -0.002 | | <0.01 | -0.003 | <0.05 | -0.001 | ns
| | • Cocaine | • used or threatened to use weapon to get something | Intact family structure | -0.009 | | <0.001 | -0.012 | <0.01 | -0.006 | <0.01
| | • Inhalants | • in a group against group fight | African American | 0.006 | | ns | 0.005 | ns | 0.006 | ns
| | • Other illicit drugs | [underlined: Instrument used to measure outcome] | Hispanic American | 0.009 | | <0.05 | 0.015 | <0.05 | 0.003 | ns
| | • Polydrug use (multiple drugs) - 2 derived indicators | None | Asian American | 0.003 | | ns | 0.008 | ns | -0.002 | ns
| | [underlined: Covariates] | [underlined: Type] | Time 1 violence | 0.073 | | <0.001 | 0.071 | <0.001 | 0.076 | <0.001
| | Gender | Physical aggression/fight, use or threat to use a weapon | Multivariate Regression w/ Cigarettes-Model 2:
| | Family structure | [underlined: Circumstance/Situational Context] | | [underlined: Time 2 violence]
| | Parent education | Not specified | | [underlined: Everyone] | | | [underlined: Male] | | [underlined: Female]
| | Age | [underlined: Proactive/Reactive] | R^2^ | 0.288 | | | 0.258 | | 0.323
| | Race | Not specified | [underlined: Factor] | [underlined: Coeff.] | | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value]
| | Ethnicity | [underlined: Weapon used] | Female gender | -0.016 | | <0.001
| | [underlined: Instrument used to measure factors:] Add Health designed questionnaire | Not specified | Age | -0.003 | | <0.001 | -0.003 | <0.05 | -0.004 | <0.001
| | | [underlined: Victim-offender relationship] | Parent education | -0.002 | | <0.01 | -0.003 | <0.05 | -0.001 | ns
| | | Not specified | Intact family structure | -0.006 | | <0.01 | -0.008 | <0.05 | -0.005 | <0.05
| | | [underlined: Adverse Health Outcome]: Not studied | African American | 0.013 | | <0.001 | 0.014 | <0.05 | 0.010 | <0.05
| | | [underlined: Are mechanisms of violence theorized?] | Hispanic American | 0.013 | | <0.001 | 0.019 | <0.01 | 0.005 | ns
| | | No | Asian American | 0.007 | | ns | 0.014 | ns | -0.000 | ns
| | | | Time 1 violence | 0.068 | | <0.001 | 0.064 | <0.001 | 0.074 | <0.001
| | | | Cigarettes | 0.005 | | <0.001 | 0.008 | <0.001 | 0.002 | <0.001
| | | | Multivariate Regression w/ Alcohol-Model 3:
| | | | | [underlined: Time 2 violence]
| | | | | [underlined: Everyone] | | | [underlined: Male] | | [underlined: Female]
| | | | R^2^ | 0.285 | | | 0.247 | | 0.327
| | | | [underlined: Factor] | [underlined: Coeff.] | | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value]
| | | | Female gender | -0.015 | | <0.001
| | | | Age | -0.003 | | <0.001 | -0.003 | <0.05 | -0.004 | <0.001
| | | | Parent education | -0.002 | | <0.01 | -0.003 | <0.01 | -0.001 | ns
| | | | Intact family structure | -0.008 | | <0.001 | -0.010 | <0.01 | -0.005 | <0.05
| | | | African American | 0.009 | | <0.01 | 0.010 | ns | 0.009 | <0.1
| | | | Hispanic American | 0.011 | | <0.01 | 0.015 | <0.05 | 0.005 | ns
| | | | Asian American | 0.006 | | ns | 0.012 | ns | -0.000 | ns
| | | | Time 1 violence | 0.068 | | <0.001 | 0.065 | <0.001 | 0.072 | <0.001
| | | | Alcohol | 0.005 | | <0.001 | 0.006 | <0.001 | 0.004 | <0.001
| | | | Multivariate Regression w/ Marijuana-Model 4:
| | | | | [underlined: Time 2 violence]
| | | | | [underlined: Everyone] | | | [underlined: Male] | | [underlined: Female]
| | | | R^2^ | 0.282 | | | 0.245 | | 0.323
| | | | [underlined: Factor] | [underlined: Coeff.] | | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value]
| | | | Female gender | -0.015 | | <0.001
| | | | Age | -0.003 | | <0.001 | -0.002 | ns | -0.003 | <0.001
| | | | Parent education | -0.002 | | <0.01 | -0.003 | <0.01 | -0.001 | ns
| | | | Intact family structure | -0.007 | | <0.001 | -0.009 | <0.05 | -0.005 | <0.05
| | | | African American | 0.007 | | <0.05 | 0.006 | ns | 0.008 | <0.1
| | | | Hispanic American | 0.010 | | <0.01 | 0.014 | <0.05 | 0.004 | ns
| | | | Asian American | 0.004 | | ns | 0.009 | ns | -0.002 | ns
| | | | Time 1 violence | 0.068 | | <0.001 | 0.065 | <0.001 | 0.073 | <0.001
| | | | Marijuana | 0.005 | | <0.001 | 0.007 | <0.01 | 0.004 | <0.01
| | | | Multivariate Regression w/ Cocaine-Model 5:
| | | | | [underlined: Time 2 violence]
| | | | | [underlined: Everyone] | | | [underlined: Male] | | [underlined: Female]
| | | | R^2^ | 0.277 | | | 0.239 | | 0.319
| | | | [underlined: Factor] | Coeff. | | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value]
| | | | Female gender | -0.014 | | <0.001
| | | | Age | -0.002 | | <0.05 | -0.001 | ns | -0.003 | <0.001
| | | | Parent education | -0.002 | | <0.01 | -0.003 | <0.05 | -0.001 | ns
| | | | Intact family structure | -0.009 | | <0.001 | -0.012 | <0.01 | -0.006 | <0.01
| | | | African American | 0.006 | | ns | 0.005 | ns | 0.007 | ns
| | | | Hispanic American | 0.009 | | <0.05 | 0.014 | <0.05 | 0.003 | ns
| | | | Asian American | 0.003 | | ns | 0.008 | ns | -0.002 | ns
| | | | Time 1 violence | 0.073 | | <0.001 | 0.071 | <0.001 | 0.075 | <0.001
| | | | Cocaine | -0.001 | | ns | -0.005 | ns | 0.007 | ns
| | | | Multivariate Regression w/ Inhalant-Model 6:
| | | | | [underlined: Time 2 violence]
| | | | | [underlined: Everyone] | | | [underlined: Male] | | [underlined: Female]
| | | | R^2^ | 0.278 | | | 0.240 | | 0.319
| | | | [underlined: Factor] | [underlined: Coeff.] | | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value]
| | | | Female gender | -0.014 | | <0.001
| | | | Age | -0.002 | | <0.05 | -0.001 | ns | -0.003 | <0.001
| | | | Parent education | -0.002 | | <0.01 | -0.003 | <0.05 | -0.001 | ns
| | | | Intact family structure | -0.009 | | <0.001 | -0.012 | <0.01 | -0.006 | <0.01
| | | | African American | 0.006 | | <0.1 | 0.005 | ns | 0.007 | ns
| | | | Hispanic American | 0.010 | | <0.05 | 0.015 | <0.05 | 0.003 | ns
| | | | Asian American | 0.003 | | ns | 0.009 | ns | -0.002 | ns
| | | | Time 1 violence | 0.071 | | <0.001 | 0.069 | <0.001 | 0.075 | <0.001
| | | | Inhalant | 0.007 | | ns | 0.008 | ns | 0.006 | ns
| | | | Multivariate Regression w/ Other Illicit Drugs-Model 7:
| | | | | [underlined: Time 2 violence]
| | | | | [underlined: Everyone] | | | [underlined: Male] | | [underlined: Female]
| | | | R^2^ | 0.278 | | | 0.239 | | 0.321
| | | | [underlined: Factor] | [underlined: Coeff.] | | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value]
| | | | Female gender | -0.015 | | <0.001
| | | | Age | -0.002 | | <0.01 | -0.001 | ns | -0.003 | <0.001
| | | | Parent education | -0.002 | | <0.01 | -0.003 | <0.05 | -0.001 | ns
| | | | Intact family structure | -0.009 | | <0.001 | -0.011 | <0.01 | -0.006 | <0.01
| | | | African American | 0.007 | | <0.1 | 0.006 | ns | 0.008 | <0.1
| | | | Hispanic American | 0.010 | | <0.01 | 0.015 | <0.05 | 0.004 | ns
| | | | Asian American | 0.003 | | ns | 0.009 | ns | -0.002 | ns
| | | | Time 1 violence | 0.071 | | <0.001 | 0.069 | <0.001 | 0.073 | <0.001
| | | | Other illicit drugs | 0.004 | | ns | 0.004 | ns | 0.005 | <0.1
| | | | Multivariate Regression w/ All Substances-Model 8:
| | | | | [underlined: Time 2 violence]
| | | | | [underlined: Everyone] | | | [underlined: Male] | | [underlined: Female]
| | | | R^2^ | 0.292 | | | 0.263 | | 0.329
| | | | [underlined: Factor] | [underlined: Coeff.] | | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value] | [underlined: Coeff.] | [underlined: p-value]
| | | | Female gender | -0.016 | | <0.001
| | | | Age | -0.004 | | <0.001 | -0.004 | <0.01 | -0.004 | <0.001
| | | | Parent education | -0.002 | | <0.01 | -0.003 | <0.01 | -0.001 | ns
| | | | Intact family structure | -0.006 | | <0.01 | -0.008 | <0.05 | -0.005 | <0.05
| | | | African American | 0.013 | | <0.001 | 0.015 | <0.01 | 0.011 | <0.05
| | | | Hispanic American | 0.013 | | <0.001 | 0.019 | <0.01 | 0.005 | ns
| | | | Asian American | 0.008 | | ns | 0.015 | ns | -0.000 | ns
| | | | Time 1 violence | 0.066 | | <0.001 | 0.062 | <0.001 | 0.070 | <0.001
| | | | Cigarettes | 0.004 | | <0.001 | 0.007 | <0.001 | 0.001 | ns
| | | | Alcohol | 0.003 | | <0.01 | 0.003 | <0.01 | 0.003 | <0.01
| | | | Marijuana | 0.002 | | ns | 0.002 | ns | 0.001 | ns
| | | | Cocaine | -0.008 | | ns | -0.014 | ns | 0.003 | ns
| | | | Inhalant | 0.005 | | ns | 0.010 | ns | 0.002 | ns
| | | | Other illicit drugs | 0.000 | | ns | -0.000 | ns | 0.002 | ns
| | | | Mean level of Time 2 Violence by prevalence of specific drug use and of polydrug use:
| | | | | [underlined: Number of substances used]
| | | | | [underlined: 0] | [underlined: 1] | [underlined: 2] | [underlined: 3] | [underlined: 4] | [underlined: 5] | [underlined: 6]
| | | | [underlined: Mean T2 Violence] | 0.054 | 0.090 | 0.124 | 0.201 | 0.214 | 0.243 | 0.550
| | | | Ever used alcohol | | 0.093 | 0.120 | 0.201 | 0.216 | 0.246
| | | | p-value* | | ns | ns | ns | ns | ns
| | | | Ever used cigarettes | | 0.084 | 0.116 | 0.200 | 0.213 | 0.236
| | | | p-value* | | ns | <0.01 | ns | ns | ns
| | | | Ever used marijuana | | 0.168 | 0.190 | 0.201 | 0.214 | 0.245
| | | | p-value* | | ns | <0.01 | ns | ns | ns
| | | | Ever used cocaine | | 0.000 | 0.180 | 0.288 | 0.246 | 0.258
| | | | p-value* | | ns | ns | <0.1 | ns | ns
| | | | Ever used inhalants | | 0.046 | 0.166 | 0.208 | 0.234 | 0.236
| | | | p-value* | | <0.1 | ns | ns | ns | ns
| | | | Ever used other drugs | | 0.334 | 0.115 | 0.169 | 0.201 | 0.242
| | | | p-value* | | <0.1 | ns | ns | ns | ns
| | | | *p-value for significance test comparing users of a drug with non-users, controlling for number of substances used
| | | | Mean level of Time 2 Violence by specific substance use and overall frequency of polydrug use:
| | | | | [underlined: Frequency score of polydrug use]
| | | | | [underlined: 0] | [underlined: 1] | [underlined: 2] | [underlined: 3] | [underlined: 4 to 5] | [underlined: 6 to 7] | [underlined: 8 to 18]
| | | | [underlined: Mean T2 Violence] | 0.054 | 0.089 | 0.103 | 0.129 | 0.153 | 0.185 | 0.298
| | | | Ever used alcohol | | 0.088 | 0.107 | 0.120 | 0.150 | 0.183 | 0.301
| | | | p-value* | | ns | ns | ns | ns | ns | <0.1
| | | | Ever used cigarettes | | 0.086 | 0.095 | 0.119 | 0.149 | 0.185 | 0.295
| | | | p-value* | | ns | ns | <0.1 | ns | ns | ns
| | | | Ever used marijuana | | 0.175 | 0.155 | 0.126 | 0.164 | 0.194 | 0.301
| | | | p-value* | | ns | <0.1 | ns | ns | <0.05 | ns
| | | | Ever used cocaine | | 0.000 | 0.118 | 0.158 | 0.197 | 0.210 | 0.373
| | | | p-value* | | ns | ns | ns | ns | ns | <0.05
| | | | Ever used inhalants | | 0.052 | 0.279 | 0.250 | 0.163 | 0.140 | 0.338
| | | | p-value* | | ns | <0.1 | <0.05 | ns | <0.05 | ns
| | | | Ever used other drugs | | 0.180 | 0.204 | 0.227 | 0.086 | 0.170 | 0.293
| | | | p-value* | | ns | ns | ns | <0.05 | ns | ns
| | | | *p-value for significance test comparing users of a drug with non-users, controlling for frequency of polydrug use
| | | | Mean level of Time 2 violence by gender and by prevalence and frequency of polydrug use:
| | | | [underlined: Mean level of T2 violence] | | | | [underlined: Mean level of T2 violence]
| | | | [underlined: Number of substances used] | | [underlined: Boys] | [underlined: Girls] | [underlined: Frequency score of polydrug use] | | [underlined: Boys] | [underlined: Girls]
| | | | 0 | | 0.07 | 0.04 | 0 | | 0.07 | 0.04
| | | | 1 | | 0.12 | 0.06 | 1 | | 0.13 | 0.05
| | | | 2 | | 0.16 | 0.08 | 2 | | 0.12 | 0.09
| | | | 3 | | 0.28 | 0.12 | 3 | | 0.17 | 0.08
| | | | 4 | | 0.30 | 0.13 | 4 to 5 | | 0.22 | 0.09
| | | | 5 | | 0.31 | 0.17 | 6 to 7 | | 0.23 | 0.14
| | | | 6 | | 0.66 | 0.41 | 8 to 18 | | 0.40 | 0.18
| | | | [underlined: Associated Adverse Health Outcome]
| | | | Not studied
Record # | Study Quality | | | Study Characteristic | Outcome (violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | | Risk Factors Studied | | Implications
| Sample Size | | | Inclusion/Exclusion Criteria
1573 | [underlined: Study Design]: Prospective cohort study; secondary data analysis of RAND Adolescent Panel Study. | | | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Ellickson 2001 J Adolescent Health | [underlined: Study Quality Score:] Poor (retention rate <80%) | | | Baseline: 1985 | [underlined: Outcome measure] | To demonstrate that smoking at grade 7 correlates with other problem behaviors both concurrently or after five years.
| [underlined: Sample size]: | | | Assessment: 1990 | • predatory violence | Weighted percentages Grade 7 non smokers (NON), Experimenters (EXP) and Smokers (SMK) with Violent Behaviors at Grade 12
| 6527 reduced to 4327 (66%) after exclusions from 30 schools at Grade 7 and assessed at Grade 12. | | | [underlined: Place (city, state):] California and Oregon | • relational violence | Total
| Nonsmoker (NON): 2230 | | | [underlined: Study Setting:] Schools | [underlined: Definition] | | NON (2230) | EXP (1322) | SMK (775)
| Experimental (EXP): 1322 | | | [underlined: Study Population]: Grade 7 students recruited from 30 schools | Predatory violence: Gang fighting, using force to get money or things from others, carrying a hidden weapon other than a pocket knife, disorderly conduct, or attacking someone with the intent to seriously harm or kill. Relational violence (hitting or threatening to hit family or non family) | % Predatory violence | 16.1 | 26.4 | 35.4
| Smoker (SMK): 775 | | | [underlined: Inclusion criteria:] | [underlined: Type:] see definition | % Relational violence | 42.5 | 57.8 | 60.1
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | | | Participate in RAND | [underlined: Circumstance/Situational Context] | Male
| [underlined: Age] | | | Adolescent Panel Study | 9-predatory violence including 4 gang fighting, 5 robbery, 3 assault, 7 relational violence | | NON (994) | EXP (703) | SMK (301)
| Grade 7 to 12 | | | [underlined: Exclusion criteria:] Dropped out of study, lost to follow-up failed to complete grade 12 survey, missing smoking information grade 7 | [underlined: Proactive/Reactive, Weapon used.] | % Predatory violence | 24.7 | 36.4 | 51.7
| [underlined: Gender]: 48% female | | | [underlined: Main independent factor(s):] | [underlined: Victim-offender relationship:] Not specified | % Relational violence | 52.9 | 64.9 | 69.6
| 52% male | | | • Smoking status | [underlined: Adverse Health Outcome]: Not studied | Female
| | Male | female | [underlined: Other risk factors:] | [underlined: Are mechanisms of violence theorized?] | | NON (1236) | EXP (619) | SMK (474)
| NON | 994 | 1236 | Academic problems: | Yes | % Predatory violence | 7.6 | 11.9 | 21.2
| EXP | 703 | 619 | • Skipped or been sent out of school | Problem Behavior Theory | % Relational violence | 32.4 | 47.5 | 51.8
| SMK | 301 | 474 | • Missed 5 + days over last year | | All are significant at p<0.05.
| [underlined: Race] | | | • Earned grades C or less | | [Multivariate analysis findings not usable because it did not separate predatory and relational violence from other problem behavior.]
| African American 10.2% | | | • Repeated grade
| Hispanic: 9.8 % | | | Substance Use:
| Asian: 8.2 % | | | • Weekly marijuana use
| White: 68% | | | • Weekly alcohol use
| Other: 4.2% | | | • Binge drinking
| | | | • Hard drug use ever
| | | | Other Problem Behavior
| | | | • Stealing
| | | | [underlined: Instruments Used]: Investigator-developed
Record # | Study Quality | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | Risk Factors Studied | | Implications
| Sample size | Inclusion/Exclusion Criteria
9629 | [underlined: Study Design:] Prospective cohort study (Rand Adolescent Panel Study - 30 California and Oregon schools) | [underlined: Study Period (begin, end):] 1985-1995 | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Ellickson 2003 Pediatrics | [underlined: Study Quality Score]: Poor (Attrition rate > 20%) | [underlined: Place (city, state):] California and Oregon | [underlined: Outcome measure] | To study the association between early adolescent drinking status (at grade 7) and later problem behavior such as violence (at grade 12).
| [underlined: Sample size]: | [underlined: Study Setting:] schools | Predatory violence, Relational violence | | | Problem Behavior At Grade 12
| Final sampe used: | [underlined: Study Population:] All 7^th^ grade students at 30 study schools who completed a survey | [underlined: Definition] | [underlined: Grade 7] | | [underlined: Predatory Violence] | [underlined: Relational Violence]
| Grade 7: 6338 | [underlined: Inclusion criteria:] see above | • Predatory violence: gang fighting, using force to get money or things from others, carrying a hidden weapon, attacking someone with the intent to seriously harm or kill | Drinking status | n | Weighted % | Weighted %
| Grade 12: 4265 (67%) | [underlined: Exclusion criteria:] | • Relational violence = hitting or threatening family or nonfamily | Nondrinkers | 1059 | 17.4^a^ | 43.9^a^
| Nondrinkers: 1059 | • Missing drinking information at grade 7 | [underlined: Type:] See definition | Experimenters | 1964 | 21.7^b^ | 51.1^b^
| Experimenters: 1964 | • Dropped out of the study at grade 12 or age 23 | [underlined: Circumstance/Situational Context; Proactive/Reactive; Weapon used; Victim-offender relationship:] Unspecified | Drinkers | 1242 | 30.8^v^ | 55.7^v^
| Drinkers: 1242 | • Lost to follow up | [underlined: Adverse Health Outcome]: Not studied | ^a,b ,v^ %'s do not share the same superscript differ at p<0.05.
| [underlined: Age]: | • Failed to complete the survey | [underlined: Are mechanisms of violence theorized?] | [The regression model lumped all problem behaviors including non-violent behavior. Thus the findings are not reported here. No adjusted p-values were reported for predatory and relational violence.]
| Baseline: grade 7 | [underlined: Main independent factor(s):] | No
| Violence outcome measured at grade 12 | Drinking status at grade 7
| [underlined: Gender]: 48% female at baseline | • Nondrinkers (never had a drink of alcohol, not even a few sips),
| [underlined: Race]: Unspecified (32% self-classified as minority at baseline) | • experimenters (drank alcohol <3 times in the past year and not in the past month), and
| | • drinkers (drank alcohol 3 or more times in the past year or drank alcohol in the past month)
| | [underlined: Instruments Used:] Investigator-developed
| | [underlined: Covariates]
| | Measured at baseline (grade 7):
| | • Demographic variables
| | • Substance use
| | • Academic problems
| | • Problem behaviors (stealing)
Record # | Study Quality | Study Characteristic | Outcome (violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | Risk Factors Studied | | Implications
| Sample Size | Inclusion/Exclusion Criteria
5894 | [underlined: Study Design]: Prospective Comparative Cohort Study | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Felson 1992 The Socio-logical Quarterly | [underlined: Study Quality Score:] | T1- 10^th^ grade students in the fall | [underlined: Outcome measure] | Examines the interrelationship between stressful life events, negative affect, and aggression.
| Good if only retention rate is considered (85%) | T2- same students 18 months later in the spring of their junior year. | Physical violence | [underlined: Zero Order Correlations, Means, and SD]
| Poor if retention rate and % used in analysis are considered (69%) | Year not specified | [underlined: Definition] | | Time 2 Variable
| [underlined: Sample size]: | [underlined: Place (city, state):] Not reported (The Youth in Transition project was started by University of Michigan, in 1966.) | An 8-time scale measure including: | [underlined: Time 1 Variable] | [underlined: Physical Aggression]
| Wave 1: N =2213 | [underlined: Study Setting:] School. | • Threatened or hurt someone | Anxiety | .08
| Wave 2: N =1883 (85%) | [underlined: Study Population] | • Hit their parents or teachers | Tension | .09
| Analysis: N=1519 (69%) | 10^th^ grade boys | • Engaged in gang fights | Somatic Symptoms | .20
| (Information obtained from #5303) | [underlined: Inclusion criteria:] Not reported | • Used weapons | Depression | .12
| [underlined: Sample size]: 1886 (sample taken from the Youth in Transition project- Bachman, 1970) | [underlined: Exclusion criteria:] Not reported | [underlined: Type:] See above | Anger | .20
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | [underlined: Main independent factor(s):] | [underlined: Circumstance/Situational Context,] | Verbal Aggression | .27
| [underlined: Age]: 10th grade students at baseline | •Anxiety (7-item scale) | Not reported | Physical Aggression | .39
| [underlined: Gender]: all male | •Tension (5-item scale) | [underlined: Proactive/Reactive] | School Deviance | .26
| [underlined: Race]- Not reported | •Depression (6-item scale) | This study is looking to correlate that frustration and stress increases the likelihood of aggression | Theft/ Vandalism | .22
| | •Somatic symptoms (18-item scale) | [underlined: Weapon used] | Mean | 123.8
| | •Anger (7-item scale) | Included in definition but not in analysis | SD | 44.7
| | [underlined: Instruments Used:] Youth in Transition questionnaire: Cronbach's alphas for the 5 independent measures are 0.76, 0.51, 0.83, 0.58, 0.63 respectively. | [underlined: Victim-offender relationship] | Standardized Coefficients Representing Effects of Distress and Anger (T1) on Behavior (T2) and controlling for behavior (T1)
| | | Not reported | | Dependent Variable
| | | [underlined: Adverse Health Outcome]: Not reported | | Physical Aggression
| | | [underlined: Are mechanisms of violence theorized?] | Anxiety | .04
| | | Yes | Tension | .06*
| | | [underlined: If yes, state the theory:] Aversive events in general lead to aggression because they produce negative affect. This emphasizes subjective states rather than external events as determinants of aggression | Symptoms | .11*
| | | | Depression | .04*
| | | | Anger | .10*
| | | | * p<.05
| | | | •Anger predicts change in aggressive behavior over time
Record # | Study Quality | Study Characteristic | Outcome (Violence) Definition and characterization | Findings
Author Year, Jnl | Group Demographics | Risk Factors Studied | | Implications
| Sample Size | Inclusion/Exclusion Criteria
634 | [underlined: Study Design]: Prospective Cohort Study (Safe Date Program) | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] | The purpose of this study is to examine predictors of adolescent dating violence from several domains guided by an ecological perspective.
Foshee 2001 Preventive Medicine | [underlined: Study Quality Score:] Fair (if 90% retention rate is used. Evidence of validity check of instrument for measuring risk factors and outcomes not provided): | • Baseline: Oct 1994; | [underlined: Outcome measure] | Domain-Specific Models for Identifying Longitudinal Predictors of Dating Violence Perpetration
| [underlined: Sample size]: | • Program activities: Nov 94 - Mar 1995; | Dating violence perpetration | | Females | Males
| Eligible: 2,434 | • Follow-up: 1 year after program activities | [underlined: Definition] | | OR+ | OR+
| Consented: 2,045 (84%) | [underlined: Place (city, state):] Johnston County, North Carolina | Violence was defined on a three-level ordinal variable on ever done the following: | Peer environment | (n=514) | (n=415)
| Baseline: 1,965 (96%) | [underlined: Study Setting:] 14 public schools | • Severe (2): Choked, burned them, hit with a fist or something hard, beat, assault with knife or gun | Friends who are victims | 1.65* | 0.75
| 1 year followup: 1759 (90%) | [underlined: Study Population:] 8^th^ and 9^th^ grade students | • Mild (1): Slapped, scratched, bent back their fingers, bit, pushed, grabbed or shoved, dumped out of a car, threw object at, forced sex, forced doing unwanted sexual things. | Friends who are perpetrators | 1.28 | 3.27**
| 1,013 subjects who met eligibility; | [underlined: Inclusion criteria:] Those who completed baseline and follow-up, who reported at follow-up that they had begun dating, who lived with a mother, and who reported at baseline that they had never been a perpetrator of dating violence | • none | Family Environment | (n=504) | (n=435)
| 931 subjects in multivariate analysis: 529 female; 402 male | [underlined: Exclusion criteria:] Not specified | [underlined: Type:] Dating violence | Family Structure | 1.14 | 0.69
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | [underlined: Main independent factor(s):] | [underlined: Circumstance/Situational Context] | Supervision by Mom | 0.79 | 0.72*
| Age: 8^th^ or 8^th^ graders | Social-environmental: | On a date | Being hit by Mom | 0.92 | 0.78
| Gender: 51.4% female | • Peer environment | Proactive/Reactive: Proactive | Being hit by an adult | 1.16 | 1.10
| Race: 77.3% white | • Family environment | [underlined: Weapon used:] Not specified | Seen a parent hit a parent | 1.04 | 1.15
| | • Social norms | [underlined: Victim-offender relationship] | Social Norms | (n=523) | (n=452)
| | Individual | a person that the respondent dated | Acceptance of prescribed norms | 1.48 | 1.92*
| | • Personal competency | [underlined: Adverse Health Outcome]: Not specified | Negative sanctions | 0.83 | 1.12
| | • Involvement in other problem behaviors | [underlined: Are mechanisms of violence theorized?] | Perceived normalcy | 1.00 | 1.44*
| | • Demographic characteristics | Ecologic perspective with 6 domains as opposed to the more typical approach of examining only individual level predictors. | Gender Stereotyping | 1.02 | 1.30
| | [underlined: Instruments used:] Investigator-developed | | Personal competencies | (n=526) | (n=443)
| | | | Self-esteem | 0.96 | 0.95
| | | | Destructive responses to anger | 1.05 | 1.60*
| | | | Poor communication skills | 1.33 | 0.93
| | | | Depressed affect | 1.21 | 0.98
| | | | Other problem behavior | (n=536) | (n=460)
| | | | Physical fight with same gender | 1.36 | 1.23
| | | | Brought weapon to school | 0.72 | 1.61
| | | | Alcohol use | 1.20 | 1.08
| | | | Demographic characteristics | (n=514) | (n=450)
| | | | Age | 1.10 | 1.13
| | | | Race | 0.59* | 0.47**
| | | | Mom education | 1.00 | 0.95
| | | | + Adjusted for other variables in the SAME domain
| | | | * significant at p=05; ** significant at p=01.
| | | | Final Cumulative Model for Identifying Longitudinal Predictors of Dating Violence Perpetration
| | | | Females (n=529)
| | | | | b | SE | OR+ | p
| | | | Intercept 1 | -2.72 | .35 | 0.00 | .000
| | | | Intercept 2 | -1.11 | .31 | 0.00 | .000
| | | | Friends who are victims | .50 | .24 | 1.65 | .035
| | | | Alcohol use | .17 | .09 | 1.19 | .046
| | | | Race | -.60 | .25 | .56 | .017
| | | | Final Cumulative Model for Identifying Longitudinal Predictors of Dating Violence Perpetration
| | | | Males (n=402)
| | | | | b | SE | OR+ | p
| | | | Intercept 1 | -2.44 | .83 | .00 | .003
| | | | Intercept 2 | -1.29 | .82 | .00 | .112
| | | | Friends who are Perpetrators | .56 | .41 | 1.75 | .171
| | | | Supervision by mom | -.12 | .18 | .89 | .494
| | | | Acceptance of prescribed Norms | .57 | .29 | 1.77 | .053
| | | | Perceived normalcy | -.33 | .19 | 1.39 | .075
| | | | Destructive responses to anger | -.03 | .22 | .97 | .894
| | | | Brought weapon to school | .33 | .32 | 1.40 | .281
| | | | Race | -.44 | .33 | .65 | .182
| | | | + Adjusted for all variables in the model.
Record # | Study Quality | Study Characteristic | Outcome (violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | Risk Factors Studied | | Implications
| Sample Size | Inclusion/Exclusion Criteria
6213 | [underlined: Study Design]: Prospective cohort study | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Halpern 1993 Social Biology | [underlined: Study Quality score]: Poor (only 50–60% of subjects were used in analysis.) | Not specified. | [underlined: Outcome measure] | The primary objective of this study was to assess the influence of pubertal increases of testosterone on aggressive behavior of adolescent males.
| [underlined: Sample size]: | 5 semiannual interviews followed by a sixth questionnaire 1 year later (about 3 years in duration) | • self reported fighting: a) fights; b) fights non-family at 6-month or 1-year follow-up. | Mean (SD) of Aggression Measures by Rounds
| Initial: 127 (≈ 50% of eligible) | [underlined: Place (city, state):] Southeastern state | • Provoked aggression scale score at the last followup. | | T (ng/dl) | Pubertal Development. | Fights | Fights Non-Family
| Analysis: 64–81 (50–64%) | [underlined: Study Setting:] interviews at subject's home | • Aggression scale scores from the Adjective Checklist and the Personality Research Form | Round* | (n=64) | (n=81) | (n=78) | (n=73)
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | [underlined: Study Population:] 7^th^ and 8^th^ grade white males age 12 and 13 in school district | [underlined: Definition:] | 1 | 157(122) | -0.83(0.98) | 2.08(1.26) | 1.65(1.30)
| Age: 12–13 year old at entry | [underlined: Inclusion criteria:] | [underlined: Instrument used to measure outcome] | 2 | 242(165) | -0.12(0.87) | 2.24(1.35) | 0.97(1.22)
| Gender: All males | [underlined: Exclusion criteria:] Parental consent not given | • Self-report on questionnaire, items taken from the Interpersonal Competence Scale-S (Cairns et al., 1989) | 3 | 294(154) | 0.17(0.82) | 2.06(1.18) | 0.89(1.24)
| Race: White | [underlined: Main independent factor(s):] | • Personality Research Form, Form E | 4 | 339(191) | 0.41(0.80) | 2.14(1.32) | 0.97(1.31)
| | • Testosterone levels | • Adjective Checklist | 5 | 369(179) | 0.65(0.83) | 2.12(1.16) | 0.87(1.30)
| | [underlined: Covariates] | • Interpersonal Competence Scale-S | 6 | 433(187) | 0.99(0.65) | 2.01(1.11) | 1.08(1.39)
| | None mentioned. | • Olweus Multifaceted Aggression Inventory (OMAI) Scales | *Round 1 ratings reflect frequency in past year. Rounds 2–6 reflect frequency in past 6 months.
| | [underlined: Instrument used to measure factors:] | [underlined: Type:] physical fighting | Repeated measure ANOVA for change scores, 6-month change periods, lagged by 6 months showed no significance difference for testosterone change, time, and pubertal change as well as the interactions between time and testosterone and pubertal change.
| | • Self-reported questionnaire | [underlined: Circumstance/Situational Context Proactive/Reactive Weapon used Victim-offender realationship:] see above
| | • Physical exam (Tanner stage) | [underlined: Adverse Health Outcome]: Not studied
| | | [underlined: Are mechanisms of violence theorized?]
| | | No
Record # | Study Quality | | Study Characteristic | Outcome (violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | Risk Factors Studied | | Implications
| Sample Size | | Inclusion/Exclusion Criteria
2658 | [underlined: Study Design]: Prospective comparative cohort study (16-year study) | | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] | [underlined: Violence outcome]
Herrenkohl 1997 Am J Ortho-psychiatry | [underlined: Study Quality Score:] | | Time 1: 1976-1977 | [underlined: Outcome measure] | To examine the relationship between preschool parenting-based variables and assaultive behavior in adolescence
| • Retention rate unknown | | Time 2: 1990-1992 | An Adolescent assaultive behavior score based on 7 items rated for frequency on a 9-point scale. Range: 0–35; mean 3.83. | Zero-order correlational relationship (R) between preschool parenting, SES, Age, and Sex and adolescent assaultive behavior:
| • % in analysis:66%–69% | | [underlined: Place (city, state):] Bethlehem, Pennsylvania | [underlined: Definition] | [underlined: Risk Factor] | [underlined: R] | [underlined: p] | [underlined: N]
| [underlined: Sample size]: | | [underlined: Study Setting:] | • Being involved in a gang fight | SES | -0.23 | p≤0.001
| Total initial sample: n=457 children from 297 families. | | Time 1: Observations of parent-child interactions in home | • Hitting parents, people at work, or others | Age | +0.14 | p≤0.01 | 418
| Final sample: | | Time 2: Unspecified | • Hitting with the idea of seriously injuring or killing | Sex | - 0.27 | p≤0.001 | 418
| Parent-child interaction: n=317 (69%); | | [underlined: Study Population:] | • Having sexual relations with someone against his or her will | Maternal discipline
| Adolescent sexual abuse: n=303 (66%) | | Preschool maltreated and non-maltreated children recruited from 5 sources: | • Using force or strong-arm methods to get money or things from people | Emotional | +0.04 | ns | 418
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | | • Child welfare abuse programs | [underlined: Instrument(s) Used] | Physical | +0.22 | p≤0.001 | 418
| [underlined: Age:] | | • Protective service programs | Items were taken from the Elliott et. Al. (1987) national survey instrument. | Mother interaction
| Time 1: Range 18 mos - 6 yrs | | • Head-Start classrooms | [underlined: Type] | Positive | +0.18 | p≤0.01 | 317
| Time 2: Range 14 – 22 yrs (90% between 14 – 20 yrs) | | • Day-care programs | Aggravated assault, non-aggravated assault, gang fight, robbery, physical aggression, rape/sexual assault | Negative | +0.27 | p≤0.001 | 317
| [underlined: Gender:] | | • Private nursery programs | [underlined: Circumstance/Situational Context, Proactive/Reactive Weapon used Victim-offender relationship] | Neglect | +0.16 | p≤0.05 | 317
| Initial sample: | | [underlined: Inclusion criteria:] Children from one of the above from a family with at least one preschool child between the ages of 18 months and 6 years | Unspecified | Regression Coefficients (β) from Multiple Regression Analysis (n=317)
| Male | n=248 (54.3%) | [underlined: Exclusion criteria]: Unspecified | [underlined: Adverse health outcome:] None | [underlined: Variable] | β | [underlined: SE](β) | [underlined: t]
| Female | n=209 (45.7%) | [underlined: Main independent factor(s):] Severity of the following domains based on mean weighted mean scores of items during the past 3 months at interview: [see finding list] | [underlined: Are mechanisms of violence theorized?] | Age | +0.20 | 0.15 | 1.37
| [underlined: Race:] | | • Mother's physical and emotional discipline | No | Sex | - 2.44 | 0.43 | -5.67****
| Initial sample: | | • Evidence of neglect | | SES | - 0.13 | 0.79 | -1.67
| White | 83% | • Occurrence of sexual abuse | | | Maternal discipline
| Spanish surname | 12% | • Quality of mother-child interactions | | Physical | +0.43 | 0.15 | 2.89**
| African American | 5% | [underlined: Covariates] | | Emotional | - 0.64 | 0.15 | <1
| | | • Age | | Neglect | +0.06 | 0.12 | <1
| | | • Sex | | Mother interaction
| | | • SES | | Negative | +0.16 | 0.07 | 2.31*
| | | | | Positive | +0.02 | 0.06 | <1
| | | | | *p<0.05; **p<0.01; ****p<0.0001.
| | | | | In a sub-sample of 235, sexual abuse was the significant risk factor (p<=0.05), replacing that of negative mother interaction.
Record# | Study Quality | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | Risk Factors Studied | | Implications
| Sample Size | Inclusion/Exclusion Criteria
2660 | [underlined: Study Design]: Prospective Comparative Cohort Study (Seattle Social Development Project (SSDP) | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] Violence at age 18 | [underlined: Violence Outcome]
Herrenkohl 2000 J Adoles-cent Health | [underlined: Study Quality Score:] Good | Baseline: 1985 | [underlined: Definition] Acts involving serious harm or threats of harm to other persons in the past year. Measured with a single dichotomous variable. | To replicate earlier research findings and to explore the effects of risk factors on violent behavior
| [underlined: Sample size]: | Follow-up: annually though 1991 and at age 18 in 1993 | [underlined: Type] | | [underlined: Unadjusted Odds Ratios (OR)]
| Eligible: 1053 | [underlined: Place (city, state):] Seattle, Washington | • Hit a teacher | [underlined: Age risk factor measured] | [underlined: 10 (703)] | [underlined: 14 (715)] | [underlined: 16 (720)]
| Participation: 808 (77%) | [underlined: Study Setting:] Looked at various domains of individual, family, school, peer, and community. | • Picked a fight* | [underlined: Risk Factor] | OR | OR | OR
| Retention: | [underlined: Study Population:] 5^th^ grade cohort from public elementary schools serving high crime areas. | • Hit someone with intent of hurting him or her* | Individual
| Age 14: 96% | [underlined: Inclusion criteria:] See above | • Threatened someone with a weapon | Male gender | 2.31*** | 2.31*** | 2.31***
| Age 16: 95% | [underlined: Exclusion criteria:] Lack of consent | • Used force or threats of force to get things from others | Hyperactive-teacher | 2.17*** | 1.98** | nd
| Age 18: 94% | [underlined: Risk factors studied:] | • Beat someone so badly he or she required medical attention. | Hyperactive-parent | 1.67 | 2.11*** | 1.96**
| Analysis: | Factors in 5 domains [see Findings column for list]: | *3 or more acts each required before a youth was identified as having committed a violent act with these indicators | Risk Taking | nd | 3.18*** | 3.50***
| Age 14: 715 (88%) | • Individual | [underlined: Instrument(s) Used, Circumstance/Situational Context; Proactive/Reactive; Weapon used; Victim-offender relationship] | Drug Selling | nd | 3.34*** | 4.55***
| Age 16: 720 (89%) | • Family | Not specified | Early Violence (12–13) | nd | 3.71*** | nd
| [underlined: Age] : | • School | Adverse Health Outcome: Not reported | Pro-Violence attitude | nd | 2.09** | nd
| Baseline: Median 10.7 | • Peer | Are mechanisms of violence theorized? | Family
| Follow-up: at 14, 16, 18 | • Community | Yes. Demonstrates the significance of non-familial social influences on violent behavior during adolescence. There is a dynamic influence of risk factors during different developmental periods. | Parental Violemce | nd | 1.84* | 1.35
| [underlined: Gender]: | [underlined: Instruments Used:] A combination of Youth Interview, school records, and Teacher/Child Behavior Checklist. | | Parent Criminal | nd | 2.16** | 2.03**
| 396 (49%) female | | | Poor family Mgmt | 1.29 | 2.11*** | 2.63***
| [underlined: Race]: | | | Family conflict | 1.05 | 1.61* | 2.16***
| Caucasian: 372 (46%) | | | Parent favored violence | 2.32** | nd | nd
| African Am: 195 (24%) | | | Residential mobility | nd | 1.32 | 2.69***
| Asian Am: 170 (21%) | | | School
| Other 72 ( 9%) | | | Low Acad Performance | 1.65* | 2.56*** | 2.71***
| | | | Low School Commitment | 1.10 | 1.87** | 1.80**
| | | | Low education aspiration | 1.20 | 1.86** | 1.60*
| | | | School transitions | nd | 1.82** | 2.97***
| | | | Antisocial behavior | 2.66*** | 2.46*** | nd
| | | | Peer
| | | | Sibling Delinquency | 1.79 | 1.40 | 2.26***
| | | | Peer Delinquency | 2.25*** | 2.82*** | 3.95***
| | | | Gang Membership | nd | 3.39*** | 4.58***
| | | | Community
| | | | Economic deprivation | 1.61* | 1.33 | 1.51*
| | | | Community disorganization | nd | 2.19*** | 3.16***
| | | | Low nghbrhd attachment | 1.54* | 1.00 | 1.69*
| | | | Available drugs | 1.77** | 2.63*** | 3.09***
| | | | Adults involved in crime | nd | 3.15*** | 3.90***
| | | | Law enforcement | nd | 1.11 | 1.38
| | | | *.p<05 **p<.01 ***p<.001 nd= not measured.
| | | | Additive risk for violence at age 18 years expressed as odds ratios (odds for violence based on comparison to “very low-risk” category)
| | | | [underlined: Number of Risk factors] | [underlined: Age 10 OR (n)] | [underlined: Age 14 OR (n)] | [underlined: Age 16 OR (n)]
| | | | 0–1 | 1.0 (268) | 1.0 (239) | 1.0 (240)
| | | | 2–3 | 3.0 (328) | 2.0 (206) | 1.8 (206)
| | | | 4–5 | 6.1 (169) | 5.9 (149) | 4.1 (139)
| | | | >5 | 10.2 ( 43) | 7.2 (214) | 10.9 (223)
Record # | Study Quality | | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | Risk Factors Studied | | Implications
| Sample Size | | Inclusion/Exclusion Criteria
6306 | [underlined: Study Design]: Prospective cohort study (3 waves of data from the Seattle Social Development Project (SSDP)) | | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] | 1. To estimate effect of early risk factors on violent behavior at age 18, as well as estimate risk factor's direct and indirect effect on violence, having controlled for predictors in each and all of the three domains at 14 yrs of age
Herrenkohl 2001 J Early Adolescence | [underlined: Study Quality Score:] Good | | T1: 1985 | [underlined: Outcome measure] | Regression coefficients (and SE) reflecting total, direct, and indirect effects of childhood risks on violent behavior at age 18
| [underlined: Sample size at assessment time points]: | | T2: 1989 | Violent behavior at age 18 | Direct Effects of Violence Controlling for: (SE)
| Study population: 1053 | | T3: 1993 | [underlined: Definition] | Risk | Total | Family | School | Peer | All
| Consented participants: | | [underlined: Place (city, state):] Seattle, WA | • Hit a teacher, | Male | .73(.18)^c^ | .76(.18) ^c^ | .70(.18) ^c^ | .68(.18) ^c^ | .67(.19) ^c^
| T1 (age 10): | 808 | [underlined: Study Setting:] school | • picked a fight, | Hyperactivity/Low attention | .83(.21) ^c^ | .79(.22) ^c^ | .60(.22) ^b^ | .73(.23) ^b^ | .58(.23) ^b^
| T2 (age 14): | 776 (96%) | [underlined: Study Population:] 5^th^ grade students from 18 Seattle public elementary schools | • hit someone with intent of hurting him/her, | Antisocial behavior | .85(.27) ^c^ | .77(.20) ^c^ | .66(.21) ^b^ | .67(.21) ^c^ | .56(.21) ^b^
| T3 (age 18): | 760 (94%) | [underlined: Inclusion criteria:] Consented to participate | • threatened someone with weapon, | Parental Attitudes Favorable toward Violence | .84(.27) ^c^ | .74(.27) ^b^ | .70(.28) ^b^ | .72(.28) ^b^ | .59(.29) ^a^
| Analysis: 808 (using missing data techniques) | | [underlined: Exclusion criteria:] Not specified | • used force or threats of force to get things from others, | Low academic Performance | .48(.19) ^b^ | .51(.19) ^b^ | .27(.20) | .42(.19) ^a^ | .31(.21)
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | | [underlined: Main independent factor(s):] | • beat someone so badly he/she requirws medical attention, | Involvement with Antisocial peers | .83(.21) ^c^ | .77(.21) ^c^ | .72(.22) ^b^ | .66(.22) ^b^ | .61(.23) ^b^
| [underlined: Ages at 3 time points]: | | [underlined: Measured at 10 yrs]: | • hit a parent | Low family income | .45(.20) ^b^ | .42(.21) ^a^ | .35(.21) | .37(.20) | .33(.21)
| T1 | 10 yrs | • male gender, | [underlined: Instrument(s) Used:] | Availability of drugs | .56(.20) ^b^ | .43(.21) ^a^ | .44(.21) ^a^ | .41(.21) | .31(.23)
| T2 | 14 yrs | • teacher-rated hyperactivity/low attention, | • Annual assessment through 1991 and at age 18 in 1993. | Low neighborhood Attachment | .45(.19) ^a^ | .42(.20) ^a^ | .45 (.20) ^a^ | .44(.20) ^a^ | .43(.21) ^a^
| T3 | 18 yrs | • teacher-rated antisocial behavior, | • Teachers' annual assessment through 1989 | ^a^ p<.05 ^b^ p<.01 ^c^ p<.001
| [underlined: Gender at T1] | | • perceived parental attitudes favorable toward violence, | • Official school records | Notes:
| 51% male | | • low academic performance, | [underlined: Type:] See definition | 1. Total effect is the bivariate estimate of each childhood risk factor with the violence outcome measure.
| 49% female | | • involvement with antisocial peers, | [underlined: Circumstance/Situational Context; Proactive/Reactive; Weapon used; Victim-offender relationship] | 2. Direct effect is the effect of each childhood risk factor's total effect mediated by each domain at 14 years of age (expressed as a change in the regression coefficient and as a percentage of the risk factor's total effect involved in that change.
| [underlined: Race at T1] | | • low family income, | Not specified except by definition | Indirect Effects of Age 10 Predictors Through: (%)
| European American | 372 (46%) | • availability of drugs in the neighborhood, | [underlined: Adverse Health Outcome]: Not addressed | Risk | Family | School | Peer | All
| African American | 195 (24%) | • low neighborhood attachment | [underlined: Are mechanisms of violence theorized?] | Male | .00 (0) | .03 (4) | .05 (7) | .06 (8)
| Asian American | 170 (21%) | [underlined: Measured at 14 yrs]: | No | Hyperactivity/low attention | .04 (5) | .23 (28) | .10 (12) | .25 (30)
| Other | 72 (9%) | • family domain (low bonding to parents, poor family management, family conflict); | | Antisocial behavior | .08 (9) | .19 (22) | .18 (21) | .29 (34)
| | | • school domain(low academic performance, low school commitment, low educational Aspirations); | | Parental Attitudes Favorable toward Violence | .10 (12) | .14 (17) | .12 (14) | .25 (30)
| | | • peer domain (involvement with antisocial peers, gang membership) | | Low academic Performance | .00 (0) | .21 (44) | .06 (13) | .18 (38)
| | | [underlined: Instrument(s) Used:] A combination of Youth Interview, school records, and Teach/Child Behavior Checklist. | | Involvement with Antisocial peers | .06 (7) | .11 (13) | .17 (21) | .22 (27)
| | | | | Low family income | .03 (7) | .10 (22) | .08 (18) | .12 (27)
| | | | | Availability of drugs | .13 (23) | .12 (21) | .15 (27) | .25 (45)
| | | | | Low neighborhood Attachment | .03 (7) | .00 (0) | .01 (2) | .02 (4)
| | | | | Note: Larger indirect effects reflect stronger mediation.
| | | | | 2. Added percentage of variance explained in violent behavior at 18 for each domain at 14 beyond that for each childhood risk
| | | | | Variance Explained | | Additional Variance Explained:
| | | | | Risk | Childhood | Family | School | Peer | All
| | | | | Male | 3.3 | 4.9 | 6.1 | 3.8 | 9.4
| | | | | Hyperactivity/Low attention | 3.7 | 4.4 | 4.7 | 3.4 | 8.2
| | | | | Antisocial behavior | 4.0 | 4.0 | 4.8 | 2.6 | 7.8
| | | | | Parental Attitudes Favorable toward Violence | 2.0 | 4.4 | 5.9 | 3.8 | 9.2
| | | | | Low academic Performance | 1.2 | 5.0 | 5.8 | 4.1 | 9.6
| | | | | Involvement with Antisocial peers | 3.7 | 4.3 | 5.5 | 2.9 | 8.4
| | | | | Low family income | 1.3 | 4.8 | 6.1 | 4.0 | 9.7
| | | | | Availability of drugs | 1.6 | 4.3 | 5.9 | 3.6 | 9.2
| | | | | Low neighborhood Attachment | 1.0 | 4.8 | 6.6 | 4.4 | 10.2
Record# | Study Quality | | | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | | Risk Factors Studied | | Implications
| Sample Size | | | Inclusion/Exclusion Criteria
10990 | [underlined: Study Design:] Prospective cohort study (a subsample of the Seattle Social Development Project cohort) | | | [underlined: Study Period (begin, end):] 1985 - 1993 | [underlined: Outcome (violence):] Youth violence at age 18 | Identify risk factors for violence and determine to what extent does exposure to multiple protective factors decreases probability of violence
Herrenkohl 2003 Social Work Research | [underlined: Study Quality Score:] Good | | | [underlined: Place (city, state):] Seattle, Washington | [underlined: Definition] | [underlined: Likelihood of violence at age 18]
| [underlined: Sample size:] Baseline: n=154 | | | [underlined: Study Setting:] 18 public elementary schools | Youth as committing any of the following violent acts in the past year: | [underlined: % Violence in]
| [underlined: At baseline:] | | | [underlined: Study Population:] Subsample of aggressive fifth grade students de fined as those scored above 3 on their childhood aggression measure. | • picked a fight | Factors at age 15 | β | SE | OR | Exposed | Not Exp
| [underlined: Age:] | 10yrs | | [underlined: Inclusion criteria:] Need consent | • hit someone with intent of hurting him or her | Community
| Gender: | N | % | [underlined: Exclusion criteria:] unspecified | • threatened someone with a weapon | Prosocial Neighborhood opportunities | .03 | .29 | 1.03 | 36 | 35
| Boys | 99 | 64 | [underlined: Main independent factors (s):] | • used force or threats of force to get things from others | Neighborhood attachment | -.63 | .46 | 0.53 | 25 | 38
| [underlined: Race:] | N | % | • Childhood aggression at age 10 | • beat someone so badly he or she required medical attention | Religious service attendance | -.73 | .40 | 0.47* | 25 | 41
| European-Am | 52 | 34 | • Factors at age 15 in the following domains (see results for individual factors) | • hit a parent | Family
| African-Am | 76 | 49 | • Community | Dichotomous variable (engaged or not engaged in violence) determined if: | Bonding to family | -.39 | .52 | 0.68 | 28 | 37
| Other/mixed | 26 | 17 | • Family | 1) engaged in three or more incidents of picking a fight and hitting someone with intent of hurting someone | Positive family involvement | -.06 | .39 | 0.94 | 34 | 35
| NOTES: Design: Students followed for eight years from 1985 with annual assessments through 1991 and a final assessment in 1993 (age 18). Data used in this study were at age 10, 15 and 18. | | | • School | 2) one or more acts of violence on the remaining indicators | Good family management | -1.25 | .50 | 0.29* | 17 | 41
| | | | • Peer | [underlined: Instrument used:] Annual assessment and school records. | School
| | | | • Prosocial beliefs | [underlined: Type:] see definition | Bonding to school | -.99 | .51 | 0.37* | 20 | 40
| | | | • Neighborhood disorganization | [underlined: Other Characteristics]: Not specified | Positive school involvement | -.07 | .43 | 0.93 | 34 | 36
| | | | [underlined: Instrument used to measure factors:] | [underlined: Adverse Health Outcome:] Not addressed | High academic achievement | -.87 | .70 | 0.42* | 20 | 37
| | | | • Child Behavior Checklist rated by teachers (10 items to form composite measure of aggression) | [underlined: Are mechanisms of violence theorized?] Yes | Peer
| | | | • Self-report to measure attachment to socialization factors (peer, family, school, community and individual) | Social Development model: risk of antisocial behavior in adolescence be reduced when youths encounter prosocial influences in the community, families, schools and peer networks. | Prosocial peer involvement | -.08 | .46 | 0.92 | 34 | 36
| | | | [underlined: Covariates] | | Individual
| | | | • Gender | | Prosocial beliefs | -.86 | .53 | 0.42 | 21 | 39
| | | | • Race/ethnicity | | Risk Factors
| | | | | | Neighborhood Disorganization | .88 | .39 | 2.41* | 48 | 28
| | | | | | Antisocial peer opportunities | .91 | .36 | 2.48* | 48 | 27
| | | | | | Antisocial peer involvement | 1.18 | .37 | 3.25 | 53 | 26
| | | | | | *p<=05
| | | | | | Probability of violence at age 18**
| | | | | | [underlined: Good Family Management at age 15]
| | | | | | | | [underlined: Exposed] | | [underlined: Unexposed]
| | | | | | African American | | 11 | | 49
| | | | | | European American | | 30 | | 32
| | | | | | Probability of violence at age 18**
| | | | | | # Protective factors
| | | | | | # Risk Factors | | 0 | 1 | 2 | 3
| | | | | | 0 | | 30 | 20 | 12 | 7
| | | | | | 1 | | 41 | 29 | 19 | 18
| | | | | | 2 | | 55 | 40 | 28 | 18
| | | | | | 3 | | 67 | 53
| | | | | | ** Estimated probability from bar graphs
| | | | | | [underlined: Associated Adverse Health Outcome]
| | | | | | None
| | | | | | [underlined: *Note:] Multiple imputation was used for missing data, Socialization factors were measured at age 15
Record # | Study Quality | Study Characteristic | Outcome (violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | Risk Factors Studied | | Implications
| Sample Size | Inclusion/Exclusion Criteria
10991 | [underlined: Study Design]: Prospective cohort study | [underlined: Study Period (begin, end):] 1990-1997 | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Herrera 2003 Violence and Victims | [underlined: Study Quality Score]: Poor (retention rate 79% | [underlined: Place (city, state):] Mid-size city, Southwestern US | 1. violent delinquency | Aim was to test the relative influence of domestic violence and physical/sexual abuse during early childhood on later violence among adolescent girls
| [underlined: Sample size]: | [underlined: Study Setting:] Place of interview not specified. Recruited by public announcements. | 2. violence against parents | [underlined: Correlations between violent outcomes and other study variables:]
| 141 Mother-daughter pairs (79%) | [underlined: Study Population:] | [underlined: Definition] | | | Violent Delinquen cy | Violence Against Parents
| (Original sample size= 179) | 55 girls whose mother reported being abused by partner. | 1. Self -reports, past year: | Variable | | r | r
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | 86 comparison girls. | Gotten in many fights | Marital violence | | NS | NS
| [underlined: Age]: 9.1 years at baseline | [underlined: Inclusion criteria:] | Physically attacked people | Physical abuse | | .21 | .40
| 14.9 yrs. at followup | Daughter lived with mother over the past year | Threatened to hurt someone | Sexual abuse | | .27 | .36
| (range: 11–18) | Between ages 6–12. | Threatened someone w/ weapon | Runaway | | .33 | .39
| [underlined: Gender:] all females | Mother and daughter consent | Hurt someone badly | Non-violent delinquency | | .49 | .42
| [underlined: Race] | [underlined: Exclusion criteria:] Specified above | 2.Self-reports, ever engaged in at least one of the following (yes/no): | [underlined: Note.] Correlation between violent delinquency and violence against parents= .43.
| 56% Anglo European | [underlined: Main independent factor(s):] | Thrown or hit something in anger | [underlined: Simultaneous Regression of Violent Delinquency]
| 34% Hispanic/ Mexican | (All measured at baseline) | Hit or pushed parent | Predictors | B | SE | β
| 4% African American | 1.Marital violence | Physically threatened parent | Age | 0.01 | 0.07 | 0.01
| 4% Native American | 2.Physical abuse on child | [underlined: Instrument used to measure outcome] Investigator-developed | Family income | 0.00 | 0.00 | -0.08
| 2% Asians, Pacific Islanders, and unclassified groups. | 3.Child sexual abuse | [underlined: The following are not specified]: Type, Circumstance/Situational Context, Proactive/Reactive, Weapon used | Marital Violence | 0.29 | 0.27 | 0.09
| | [underlined: Instrument used to measure factors:] | [underlined: Victim-offender relationship] | Physical abuse | 0.46 | 0.29 | 0.14
| | 1. Modified Conflict Tactics Scale (CTS) (Mother's report) | #1 is violence on anyone | Sexual abuse | 0.84 | 0.29 | 0.25*
| | 2. CTS “Escalated abuse” tactics. (Mother and child's report on paternal abuse, child's report of maternal abuse.) | #2 is violence on parents | Note. R-squared model= .10; F (5, 135) = 3.29, p= .0007.
| | 3. No instrument used. Open-ended questions for mothers and daughters. | [underlined: Adverse Health Outcome:]: (not abstractable) | *p< .001
| | [underlined: Covariates] | [underlined: Type:] physical injury | [underlined: Simultaneous Regression of Violence Against Parents]
| | family income, age | [underlined: Definition:] hurting someone badly enough that victim needed bandages or a doctor. | Predictors | B | χ^[underlined: 2]^ | OR
| | | [underlined: Are mechanisms of violence theorized?] | Age | 0.11 | 1.10 | 1.12
| | | No. | Family income | 0.00 | 0.04 | 1.00
| | | | Marital Violence | 0.16 | 0.16 | 1.17
| | | | Physical abuse | 0.93 | 5.24 | 2.54*
| | | | Sexual abuse | 0.53 | 1.59 | 1.70
| | | | Note. χ^2^ model (5df)= .13.48, p= .01
| | | | *p< .05.
Record # | Study Quality | | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | Risk Factors Studied | | Implications
| Sample size | | Inclusion/Exclusion Criteria
8540 | [underlined: Study Design]: Prospective cohort study (Seattle Social Development Project (SSDP)) | | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] Violent behavior at age 18 yrs | [underlined: Violence Outcome]
Huang 2001 Criminology | [underlined: Study Quality Score:] Good | | Baseline: 1985 | [underlined: Definition] | [underlined: Factor correlation with violence at age 18 (12)]
| [underlined: Sample size]: | | Follow-ups: 1988, 1989, 1991, and 1993 | • Picking a fight with someone, | Number | Factor | R | p-value
| Study population: | 1053 | [underlined: Place (city, state):] Seattle, WA | • hitting someone with the intention of hurting, | 1. | Violent behavior (age 10) | .23 | <.001
| Acceptance of participation: | 808 | [underlined: Study Setting:] | • beating someone so badly that a doctor's help was needed, and | 2. | Prosocial opportunities | - .07 | ns
| Analysis: | 807 | • 5^th^ grade survey-group administered in school | • threatening someone with a gun | 3. | Antisocial opportunities | .36 | <.001
| [underlined: Age:] | | • Follow-up individual interviews in person | [underlined: Type:] See definition | 4. | Prosocial involvement | - .09 | <.05
| 1985: 10 | | [underlined: Study Population:] 5^th^ grade students enrolled in 18 Seattle elementary schools in 1985 | [underlined: Circumstance/Situational Context; Proactive/Reactive;Weapon used] | 5. | Antisocial involvement | .39 | <.001
| 1988: 13 | | [underlined: Inclusion criteria:] Student and parent consent to participate in study | See definition | 6. | Skills for interaction | - .31 | <.001
| 1989: 14 | | [underlined: Exclusion criteria:] Not specified | [underlined: Victim-offender relationship:] Not specified | 7. | Prosocial rewards | - .19 | <.001
| 1991: 16 | | [underlined: Main independent factor(s):] | [underlined: Adverse Health Outcome]: Not addressed | 8. | Antisocial rewards | .28 | <.001
| 1993: 18 | | • Early violent behavior at age 10 and 13 | [underlined: Are mechanisms of violence theorized?] | 9. | Prosocial bonding | - .22 | <.001
| [underlined: Gender] | | • Prosocial and antisocial opportunities | Yes | 10. | Antisocial bonding | .17 | <.001
| Male | 411 | • Prosocial and antisocial involvement | [underlined: If yes, state the theory:] The social development model (SDM) integrates key features of differential association, social learning, and social control theories to more fully describe causal and mediating processes hypothesized to predict behavior over the course of development (Catalano and Hawkins, 1996). The SDM hypothesizes parallel developmental processes leading to prosocial and antisocial outcomes. | 11. | Belief in the moral order | - .31 | <.001
| Female | 396 | • Skills for interaction | | 13. | Violent behavior (age 13) | .38 | <.001
| [underlined: Race] | | • Prosocial and antisocial rewards | | [underlined: Structural Path Estimates]
| White | 46% | • Prosocial and antisocial bonding | | Path | path coefficients | Path | Path coefficient
| Black | 24% | • Belief in the moral order | | 1→12 | .15*
| Asian-American | 21% | [underlined: Instrument(s) Used:] A combination of Youth Interview, school records, and Teach/Child Behavior Checklist | | 1→2 | - .13** | 2→4 | .85***
| Native American | 6% | [underlined: Covariates] | | | | 4→7 | .76***
| Other | 3% | Gender | | | | 7→9 | .40***
| | | Ethnicity | | | | 9→11 | .53***
| | | | | | | 11→12 | - .17***
| | | | | 1→3 | .56*** | 3→5 | .80***
| | | | | | | 5→8 | .38***
| | | | | | | 8→10 | .24***
| | | | | | | 10→11 | - .08*
| | | | | | | 11→12 | - .17***
| | | | | 6→7 | .26*** | 7→9 | .40***
| | | | | | | 9→11 | .53***
| | | | | | | 11→12 | - .17***
| | | | | 6→8 | -.55*** | 8→10 | .24***
| | | | | | | 10→11 | - .08*
| | | | | | | 11→12 | - .17***
| | | | | 10→12 | .04
| | | | | 8→12 | .16**
| | | | | *<.05; **<.01; ***<.001
| | | | | [Second-order factor model findings not reported here]
Record# | Study Quality | | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | Risk Factors Studied | | Implications
| Sample Size | | Inclusion/Exclusion Criteria
10619 | [underlined: Study Design]: Prospective cohort study (offspring of cohort of 7th graders from Houston Independent School Districts) | | [underlined: Study Period (begin, end):] Interviews initiated in 1994, followup interview in 1997 | [underlined: Outcome (violence):] Fights in the last year at 3 year follow-up | [underlined: (A) Zero-Order Correlation of Behavioral Variables at Baseline Controlling for Demographic Variables for Total Sample]
Kaplan 2001 Criminology | [underlined: Study Quality Score:] Poor (retention rate <80%) | | [underlined: Place (city, state):] Houston, Texas | [underlined: Definition] | | [underlined: Correlation with Fights]
| [underlined: Sample size]: | | [underlined: Study Setting:] | Fist fights, gang fights and beating up someone within the last year | Variable at Baseline | Reported at 3 Year Follow-up
| Eligible: 6359 | | [underlined: Study Population:] Offspring of a study cohort who had been followed since 7th grade from 18 of 36 junior high schools in 1971 | [underlined: Instrument used to measure outcome:] Investigator-developed | Alcohol use | .017 | ns
| Baseline: 5887 | | [underlined: Inclusion criteria:] consented to participate | [underlined: Type:] see definition | Marijuana use | .017 | ns
| 3 year follow-up: 2,222 (38%) | | [underlined: Exclusion criteria:] None | [underlined: Circumstance/Situational Context] | Illicit drug use | .041 | ns
| [underlined: Age]: | | [underlined: Main independent factor(s):] | [underlined: Proactive/Reactive] | Carrying weapon | .053 | <.05
| At time of initial interview: | | At baseline, use in past year: | [underlined: Weapon used] | Fights | .186 | <.05
| Age | % | • Alcohol use (score 0 to 15) | [underlined: Victim-offender relationship] | [underlined: (B) Structural Model of Standardized Effects of Early Substance Use on Later Violence]
| 12 | 22% | • Marijuana use (0 to 5) | Not specified | Pathway | Coefficients
| 13–14 | 25% | • Illicit drug use (0 to 65) | [underlined: Adverse Health Outcome]: Substance use after violence. See (C) under Findings. | T1Substance use→T2Fights | -.35 | <.05
| 15–16 | 21% | • Carrying weapons (0 to 5) | [underlined: Are mechanisms of violence theorized?] | T1Violence*→T2Fights | .82 | <.05
| 17–18 | 16% | • Fights (0 to 15) | Yes | * included both weapon carrying and fights.
| 19–20 | 9% | [underlined: Instrument used to measure factors:] Investigator-developed | The theoretical model hypothesized positive within-wave relationships between substance use and violence and a direct INVERSE effect of substance use at time 1 on violence at time 2. They hypothesized inverse effects of drug use on later violence was predicated primarily on the assumptions that motivation to engage in violence is associated with distressful self-feelings, that negative self-feelings motivate substance use, and that substance use functions to alleviate the negative self-feelings associated with the disposition to engage in violence. The findings support this theoretical orientation. | [underlined: (C) Structural Model of Standardized Effects of Violence on Concurrent and Later Substance Use]
| >20 | 7% | [underlined: Covariates] | | Pathway | Coefficients
| [underlined: Gender]: | | Gender | | T1Violence*↔T1Substance Use | .67 | <.05
| 49% male | | Black | | T1Violence*→T2Substance Use | .06 | ns
| 51% female | | Latino | | T2Violence*↔T2Substance Use | .43 | <.05
| [underlined: Race]: | | Social class (1 lowest; 6 highest) | | *included both weapon carrying and fights.
| 45% white
| 38% African American
| 16% Mexican American
Record # | Study Quality | | Study Characteristic | Outcome (violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | Risk Factors Studied | | Implications
| Sample Size | | Inclusion/Exclusion Criteria
6595 | [underlined: Study Design:] Prospective cohort study (2^nd^ and 3^rd^ waves of a longitudinal study of 6^th^ and 7^th^ grade boys residing in South Florida which began in 1990.) | | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] | [underlined: To test the hypothesis that blacks are more violent than whites within a similar socio-cultural context in an urban area.]
Kingery 1996 Social Psychology International | [underlined: Study Quality Score:] Poor (Attrition rate >20%) | | Baseline - 1990 | Violence-related behaviors | Ethnicity | N | Gang fight | Used force | Beat Someone
| [underlined: Sample size:] | | Time 2 - Fall, 1991 | At time 2 and 3 measured over the past month. | All Ethnicities | 4071 | 8.1 | 6.8 | 8.5
| Eligible: 9763 | | Time 3 - Spring, 1993 | [underlined: Definition] | Cuban | 1172 | 8.0 | 5.6 | 6.8
| Baseline n=6760 (69%) | | [underlined: Place (city, state):] Dade County, Florida | • Taking part in gang fights | Other Hispanic | 1109 | 8.9* | 7.7 | 8.3
| Final sample n=3955 (59% of baseline) | | [underlined: Study Setting:] middle schools | • Using force to get money or items | US Black | 503 | 6.1 | 8.1 | 10.2
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | | [underlined: Study Population] | • Beating someone up for no reason | White | 640 | 6.3 | 6.6 | 9.3
| [underlined: Age:] | | Inner-city male adolescents living in South Florida (around Miami) | [underlined: Type] | Haitian | 96 | 10.6 | 8.5 | 7.4
| Baseline measured at grades 6 and 7 | | [underlined: Inclusion criteria:] All 6^th^ and 7^th^ grade males from 48 middle schools in Dade county | • Aggravated assault | Caribbean Black | 110 | 10.4 | 9.3 | 13.9
| Violence outcome measured at grade 8 (n=1704) and grade 9 (n=2251) ) | | [underlined: Exclusion criteria:] | • Non-aggravated assault | Nicaraguan | 340 | 10.7* | 6.0 | 10.7
| [underlined: Gender]: 3955 male (100%) | | • Female adolescents | • Gang fight | Other | 101 | 7.1 | 6.1 | 4.0
| [underlined: Race:] | | • Did not return consent forms | • Robbery | * p<0.05 by Chi-square test.
| Cuban: | 1172 (28.8%) | • Parents did not allow participation | [underlined: Circumstance/Situational Context; Proactive/Reactive; Weapon used; Victim-offender relationship:] Unspecified | Stepwise logistic regression results not used because the composite violent score included carrying a weapon which is a non-violent behavior according to the Task Order definition.
| Non-Cuban Hisp: | 1109 (27.2%) | • Moved away or out of the school system before the conclusion of the study | [underlined: Adverse Health Outcome:] Not Studied
| American Black: | 503 (12.4%) | • Absent during second and third wave data collection | [underlined: Are mechanisms of violence theorized?]
| White: | 640 (15.7%) | • Admitted to answering questions dishonestly | Yes
| Haitian: | 96 ( 2.4%) | • Missing key response components of the violence composite | The study attempts to dispel the “race hypothesis” and show that race and ethnicity do not play a large role in weapon carrying and interpersonal violence among young adolescent boys living under the same deprivations.
| Caribbean Black: | 110 ( 2.7%) | [underlined: Main independent factor(s):]
| Nicaraguan: | 340 ( 8.4%) | • Race/ethnicity
| Others: | 101 ( 2.5%) | • Normative values (Normative Values Scale by Kaplan 1986)
| | | • Derogation (Kaplan's Derogation Scales)
| | | • Cocaine & crack use (composite score by author)
| | | • Marital & education status of parents
| | | • Grade in school
| | | • Beliefs (several levels)
| | | • Behaviors (Likelihood that, when insulted by someone, would hit them or try to get even)
| | | [underlined: Instruments Used:] Indicated above
Record # Author Year, Jnl | Study Quality | | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
| Group(s) Demographics | | Risk Factors Studied | | Implications
| Sample Size | | Inclusion/Exclusion Criteria
6638 | [underlined: Study Design]: Prospective cohort study (part of a 9-year community trial, Project Northland, in rural northeastern Minnesota) | | [underlined: Study Period (begin, end):] Spring 1994 and 1995 (8^th^ and 9^th^ grades) | [underlined: Outcome (violence):] Violence behaviors | Longitudinal associations between race, gender, MMPI-A high risk status, and alcohol use with violent behavior
Komro 1999 J Child & Adolescent Substance Abuse | [underlined: Study Quality Score:] Poor (attrition > 20%) | | [underlined: Place (city, state):] Rural Northeastern Minnesota | [underlined: Definition] | [underlined: (A) Alcohol Use]
| [underlined: Sample size]: | | [underlined: Study Setting:] Classroom-based in 10 school districts | • Hit or beat up someone | Independent factors | N | OR | (95%CI)
| Initial cohort: 1266 | | [underlined: Study Population:] 8^th^ and 9^th^ grade students | • Pulled a weapon such as gun or knife on someone | Race
| Both surveys: 1088 | | [underlined: Inclusion criteria:] see above | [underlined: Type:] Physical aggression | Other | 27 | 1.00
| Analysis sample: 937 (74% of initial cohort; 86% of those completed both surveys) | | [underlined: Exclusion criteria]: | [underlined: Circumstance/Situational Context:] | White | 896 | 0.29 | (0.12, 0.70)
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | | • Did not complete a survey in both 8^th^ and 9^th^ grade | [underlined: Proactive/Reactive; Victim-offender relationship:] | Gender
| [underlined: Age]: | | • Moved between intervention and reference conditions | Unspecified | Girls | 455 | 1.00
| 9th grade students (study also reports non violence-related outcomes of same cohort measured in 8th grade) | | • Did not meet criteria for valid responding (i.e., response inconsistencies or exaggerations) | [underlined: Weapon used] | Boys | 468 | 2.78 | (2.09, 3.72)
| [underlined: Gender:] | | [underlined: Main independent factor(s):] | Hitting, Threatening (with gun or knife) | MMPI-A risk status
| Male: | 51% (478) | • MMPI-A (the Minnesota Multiphasic Personality Inventory-Adolescent) classification on 5 scales: | [underlined: Adverse Health Outcome]: Not studied | Low | 611 | 1.00
| Female: | 49% (459) | 1. Family Problems Scale | [underlined: Are mechanisms of violence theorized?] | High** | 312 | 2.40 | (1.76, 3.28)
| [underlined: Race]: | | 2. School Problems Scale | No | Alcohol use
| White: | 97% (909) | 3. Low Aspirations Scale | | None in past mo. | 663 | 1.00
| American Indian: | 2% (19) | 4. Alcohol/Drug Problem Proneness Scale | | Use past mo./no binge drinking | 168 | 1.33 | (0.92, 1.93)
| Other: | 1% (9) | 5. Alcohol/Drug Problem Acknowledgement Scale | | Use past mo./binge drinking | 92 | 2.06 | (1.26, 3.36)
| | | • Alcohol use: | | [underlined: (B) Acknowledgment of Alcohol/Drug Problems Use]
| | | 1. Past month alcohol use | | Race
| | | 2. Binge drinking (5 or more drinks in a row in the last 2 weeks) | | Other | 24 | 1.00
| | | [underlined: Covariates] | | White | 880 | 0.21 | (0.08, 0.57)
| | | • Race | | Gender
| | | • Gender | | Girls | 450 | 1.00
| | | [underlined: Instruments Used]: see above | | Boys | 454 | 2.83 | (2.11, 3.79)
| | | | | MMPI-A risk status
| | | | | Low | 588 | 1.00
| | | | | High** | 316 | 2.36 | (1.71, 3.26)
| | | | | Acknowledgment of Alcohol/drug problem use
| | | | | Low | 813 | 1.00
| | | | | High | 91 | 2.15 | (1.29, 3.57)
| | | | | **MMPI-A high risk status is defined as students with at least one elevated MMPI-A scales score on four MMPI-A scales
| | | | | Note: Rates of having ever “pulled a weapon such as a gun or knife on someone” were too low for the results of logistic regression analysis to be valid.
Record# | Study Quality | | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | Risk Factors Studied | | Implications
| Sample Size | | Inclusion/Exclusion Criteria
9560 | [underlined: Study Design]: Prospective cohort study (3 year follow-up data from the Pittsburgh Youth Study) | | [underlined: Study Period (begin, end):] 1987-1990 | [underlined: Outcome (violence):] Violence for the study period (age 16) | [underlined: Violence Outcome]
Loeber 1993 Development and Psycho-pathology | [underlined: Study Quality Score:] Good | | [underlined: Place (city, state):] Pittsburgh, PA | [underlined: Definition] | To identify developmental pathways in disruptive child behavior, such as violence.
| [underlined: Sample size]: | | [underlined: Study Setting:] Public schools | •Attacking someone | [underlined: Overt pathway behavior rates]
| 7th grade cohort: 506 | | [underlined: Study Population:] A sample of 1^st^, 4^th^, and 7^th^ grade boys enrolled in Pittsburgh public schools and their primary caretakers (Only the 7th grade cohort findings are reported here). | •Strong arming | Behavior | African Amer N (%) | Caucasian N (%) | p-value for Chi-sq
| Analysis: 435 (86%) | | [underlined: Inclusion criteria]: see above | •Forcing sex | Aggression | 116 (29.9) | 102 (47.4) | ns
| [underlined: Age]: | Mean (SD) | [underlined: Exclusion criteria]: None | [underlined: Instrument used to measure outcome] | Fighting | 132 (45.4) | 72 (33.5) | <0.01
| | 13.4 (0.9) | [underlined: Main independent factor(s):] | • Self-reported Delinquency Scale | Violence | 72 (24.7) | 28 (13.0) | <0.01
| [underlined: Gender]: | 100% male | • Aggression | [underlined: Type:] see definition | [underlined: Overt pathway sequence* for those showing 1 or more forms of overt behavior]
| [underlined: Race]: | | • Fighting | Not specified | Behavior | Total N (%) | Afric-Amer N (%) | Caucasian N (%)
| African Amer | 291 (57.5%) | [underlined: Instrument used to measure factors:] | [underlined: Circumstance/Situational Context; Proactive/Reactive Weapon used: Victim-offender relationship:] Not specified | • Sequences starting with Aggression
| Caucasian | 215 (42.5%) | • Maternal Child Behavior Checklist | [underlined: Adverse Health Outcome]: Not studied | A→F→V | 15 ( 5.3) | 12 ( 7.0) | 3 ( 2.7)
| | | • Diagnostic Schedule for Children-revised | [underlined: Are mechanisms of violence theorized?] | A→F | 48 (17.0) | 23 (13.5) | 25 (22.3)
| | | • Self-reported Delinquency Scale | Yes | A only | 73 (25.8) | 32 (18.7) | 41 (36.6)
| | | • Youth Self Report | [underlined: If yes, state the theory:] | A→V | 9 ( 3.2) | 3 ( 1.8) | 6 ( 5.4)
| | | [underlined: Covariates] | Violent behavior develops via the overt pathway: | Total | 145 (51.2) | 70 (40.9) | 75 (67.0)
| | | • Age group | 1: Aggression (annoying others, bullying) | • Sequences starting with Fighting
| | | • Race | 2: Fighting (physical fighting, gang fighting) | F→V | 24 ( 8.5) | 18 (10.5) | 6 ( 5.4)
| | | | 3: Violence | F only | 47 (16.6) | 32 (18.7) | 15 (13.4)
| | | | | Total | 71 (25.1) | 50 (29.2) | 21 (18.8)
| | | | | • Sequences starting with Violence
| | | | | V only | 13 ( 4.6) | 11 ( 6.4) | 2 ( 1.8)
| | | | | • Nonfitting sequences | 54 (19.1) | 40 (23.4) | 14 (11.8)
| | | | | • No overt behavior | 152 (34.9) | 86 (33.5) | 66 (37.1)
| | | | | Sample size | 435 | 257 | 178
| | | | | *A=Aggression
| | | | | F=Fighting
| | | | | V=Violence
Record # | Study Quality | | Study Characteristic | Outcome (violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | Risk Factors Studied | | Implications
| Sample Size | | Inclusion/Exclusion Criteria
6855 | [underlined: Study Design] Prospective cohort study (Joint analysis of 3 longitudinal studies: Pittsburgh Youth Study, Denver Youth Survey, and Rochester Youth Development Study) | | [underlined: Study Period (begin, end):] 1987-1993 | [underlined: Outcome (violence):] Violent behavior | To replicate a developmental pathway to violent juvenile delinquency across different studies.
Loeber 1999 Studies on Crime and Crime Prevention | [underlined: Study Quality Score:] Poor (attrition rate >20%) | | [underlined: Place (city, state):] Pittsburgh, PA | [underlined: Definition] | Prevalence of behaviors:
The Pittsburgh Youth Study | [underlined: Sample size] | | [underlined: Study Setting:] Public schools | •Attacking someone | | [underlined: Fighting (Step 2)] | | [underlined: Violence (Step 3)]
| Pittsburgh: | | [underlined: Study Population:] Adolescent males | •Strong-arming | | # (%) | p-value for racial diff. | # (%) | p-value for racial diff.
| Baseline: 506 (84.7% of eligible) | | [underlined: Inclusion criteria:] Boys randomly drawn from the 7^th^ grades, over-sampled “at risk” population; A total of 9 assessments: 6-months for first 6 follow-up and yearly thereafter | •Rape | Pittsburgh, PA | N=447 | <0.01 | N=417 | <0.0001
| Analysis: 365 (72%) | | [underlined: Exclusion criteria:] None | [underlined: Instrument used to measure outcome] | Total | 268 (60.0) | | 155 (37.2)
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | | [underlined: Main independent factor(s):] | • 37 -item Self-Reported Delinquency Scale (SRD), scale used by National Youth Survey. | African American | 172 (65.6) | | 108 (44.3)
| Age: Not specified | | • Age of onset of physical fighting gang fighting or violent behavior | • Extended version of the Material Child Behavior Checklist (Pittsburgh only) | Caucasian | 96 (51.9) | | 47 (27.2)
| Gender: 100% Male | | • Overt developmental pathway | • Extended version of the Youth Self-Report (Pittsburgh only) | Fit in the overt developmental pathway:
| Race: | | 1. Persisters: Those who engaged in any violent behavior at more than 1 annual assessment. | • Parent version of the Diagnostic Interview Schedule for Children (Pittsburgh only) | Pittsburgh, PA
| Pittsburgh | | 2. Experimenters: Those who engaged in any violent behavior only once. | [underlined: Type:] Rape, attack | [underlined: Persisters:] | [underlined: Steps 2 to 3] | [underlined: Step 2 only] | [underlined: Step 3 only] | [underlined: Total]
| African Amer | 291 (57.5%) | 3. Nonfitters: Those whose ordering of reported behaviors was the inverse of that postulated by the overt development pathway. | [underlined: Circumstance/Situational Context; Proactive/Reactive; Weapon used; Victim-offender relationship:] Not specified | | # (%) | # (%) | # (%) | # (%)
| Caucasian | 215 (42.5%) | [underlined: Instrument used to measure factors:] See Instruments used to measure outcome | [underlined: Adverse Health Outcome:] Not studied | Total | 76 (15.0) | 65 (12.8) | 4 ( 0.8) | 145 (28.7)
| Total | | [underlined: Covariates] | [underlined: Are mechanisms of violence theorized?] | Afr Amer | 53 (18.2) | 40 (13.7) | 3 ( 1.0) | 96 (33.0)
| African Amer | 916 (53.9%) | Race | Yes | Caucasian | 23 (10.7) | 25 (11.6) | 1 ( 0.5) | 49 (22.8)
| Caucasian | 380 (22.4%) | | Overt pathway to boys' violent behavior stems from minor aggression (step 1) to physical fighting (step 2) to violent behavior (step 3). | | [underlined: Exper.:] | [underlined: Excl./miss] | [underlined: Nonfitters:] | [underlined: No overt behav.:]
| Hispanic | 357 (21.0%) | | | | # (%) | # (%) | # (%) | # (%)
| Other | 46 ( 2.7%) | . | | Total | 73 (14.4) | 37 ( 7.3) | 41 ( 8.1) | 210 (41.5)
| | | | | Afr Amer | 41 (14.1) | 21 ( 7.2) | 31 (10.7) | 102 (35.1)
| | | | | Caucasian | 32 (14.0) | 16 ( 7.4) | 10 ( 4.7) | 215 (22.8)
| | | | | [underlined: Entry into overt developmental pathway:]
| | | | | Looking at proportion of Persisters and Experimenters entering at Step 2:
| | | | | | [underlined: Proportion (%)]
| | | | | Pittsburgh | 90
| | | | | Denver | 98
| | | | | Rochester | 98
| | | | | Comparing Persisters with Experimenters on the proportion entering at Step 2*:
| | | | | | [underlined: Odds ratios (95%CI)]
| | | | | Pittsburgh | 11.5 (3.7–35.7)
| | | | | Denver | Not reported
| | | | | Rochester | 10.1 (1.9–52.6)
| | | | | *Details on regression model not provided in study.
The Denver Youth Survey | [underlined: Study Design] Prospective cohort study (Joint analysis of 3 longitudinal studies: Pittsburgh Youth Study, Denver Youth Survey, and Rochester Youth Development Study) | | [underlined: Study Period (begin, end):] 1987-1993 | [underlined: Outcome (violence):] Violent behavior | To replicate a developmental pathway to violent juvenile delinquency across different studies.
| [underlined: Study Quality Score:] Good | | [underlined: Place (city, state):] Denver, CO | [underlined: Definition] | Prevalence of behaviors:
| [underlined: Sample size] | | [underlined: Study Setting:] Households in high risk neighborhoods | • Attacking someone | | [underlined: Fighting (Step 2)] | | [underlined: Violence (Step 3)]
| Denver: | | [underlined: Study Population:] Adolescent males | • Strong arming | | # (%) | p-value for racial diff. | # (%) | p-value for racial diff.
| Baseline: 464 | | [underlined: Inclusion criteria:] Boys aged 11, 13, or 15 at time of study enrollment; first 5 yearly interviews were analyzed. | • Rape | Denver, CO | N=419 | ns | N=382 | <0.0001
| Analysis 373 (80%) | | [underlined: Exclusion criteria:] None | [underlined: Instrument used to measure outcome] | Total | 248 (59.2) | | 66 (17.3)
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | | [underlined: Main independent factor(s):] | • 37-item Self-Reported Delinquency Scale (SRD), improved version of the SRD scale used by National Youth Survey. | African American | 95 (65.5) | | 36 (27.9)
| Age: Not specified | | • Age of onset of physical fighting, gang fighting or violent behavior. | [underlined: Type] | Caucasian | 16 (53.3) | | 2 ( 6.9)
| Gender: 100% Male | | • Overt developmental pathway. | Rape, attack | Hispanic | 117 (57.9) | | 27 (14.5)
| Race: | | 1. Persisters: Those who engaged in any violent behavior at more than 1 annual assessment. | [underlined: Circumstance/Situational Context; Proactive/Reactive; Weapon used; Victim-offender relationship:] Not specified | Other | 20 (47.6) | | 1 ( 2.6)
| Denver | | 2. Experimenters: Those who engaged in any violent behavior only once. | [underlined: Adverse Health Outcome:] Not studied | Fit in the overt developmental pathway:
| African Amer | 161 (34.7%) | 3. Nonfitters: Those whose ordering of reported behaviors was the inverse of that postulated by the overt development pathway. | [underlined: Are mechanisms of violence theorized?] | Denver, CO
| Caucasian | 31 ( 6.7%) | [underlined: Instrument used to measure factors:] See Instruments used to measure outcome | Yes | [underlined: Persisters:] | [underlined: Steps 2 to 3] | [underlined: Step 2 only] | [underlined: Step 3 only] | [underlined: Total]
| Hispanic | 226 (48.7%) | [underlined: Covariates] | Overt pathway to boys' violent behavior stems from minor aggression (step 1) to physical fighting (step 2) to violent behavior (step 3). | | # (%) | # (%) | # (%) | # (%)
| Other | 46 ( 9.9%) | Race | | Total | 47 (10.1) | 107 (23.1) | 2 ( 0.4) | 156 (33.6)
| Total | | | | Afr Amer | 25 (15.5) | 38 (23.6) | 2 ( 1.2) | 65 (40.4)
| African Amer | 916 (53.9%) | | | Caucasian | 1 ( 3.2) | 7 (22.6) | 0 ( 0.0) | 8 (25.8)
| Caucasian | 380 (22.4%) | | | Hispanic | 21 ( 9.3) | 52 (23.0) | 0 ( 0.0) | 73 (32.3)
| Hispanic | 357 (21.0%) | | | Other | 0 ( 0.0) | 10 (21.7) | 0 ( 0.0) | 10 (21.7)
| Other | 46 ( 2.7%) | | | | [underlined: Exper.:] | [underlined: Excl./miss.:] | [underlined: Nonfitters.:] | [underlined: No overt behav.:]
| | | | | | # (%) | # (%) | # (%) | # (%)
| | | | | Total | 58 (12.5) | 34 ( 7.3) | 7 ( 1.5) | 209 (45.0)
| | | | | Afr Amer | 21 (13.0) | 11 ( 6.8) | 3 ( 1.9) | 61 (37.9)
| | | | | Caucasian | 5 (16.1) | 2 ( 6.5) | 1 ( 3.2) | 15 (48.4)
| | | | | Hispanic | 26 (11.5) | 17 ( 7.5) | 3 ( 1.3) | 107 (47.3)
| | | | | Other | 6 (13.0) | 4 ( 8.7) | 0 (0.0) | 26 (56.5)
| | | | | Entry into overt developmental pathway:
| | | | | Looking at proportion of Persisters and Experimenters entering at Step 2:
| | | | | | [underlined: Proportion (%)]
| | | | | Pittsburgh | 90
| | | | | Denver | 98
| | | | | Rochester | 98
| | | | | Comparing Persisters with Experimenters on the proportion entering at Step 2*:
| | | | | | [underlined: Odds ratios (95%CI)]
| | | | | Pittsburgh | 11.5 (3.7–35.7)
| | | | | Denver | Not reported
| | | | | Rochester | 10.1 (1.9–52.6)
| | | | | *Details on regression model not provided in study.
The Rochester Youth Development Study | [underlined: Study Design] Prospective cohort study (Joint analysis of 3 longitudinal studies: Pittsburgh Youth Study, Denver Youth Survey, and Rochester Youth Development Study) | | [underlined: Study Period (begin, end):] 1987-1993 | [underlined: Outcome (violence):] Violent behavior | To replicate a developmental pathway to violent juvenile delinquency across different studies.
| [underlined: Study Quality Score:] Poor (attrition rate >20%) | | [underlined: Place (city, state):] Rochester, NY | [underlined: Definition] | Prevalence of behaviors:
| [underlined: Sample size] | | [underlined: Study Setting:] Public schools | • Attacking someone | | [underlined: Fighting (Step 2)] | | [underlined: Violence (Step 3)]
| Rochester: | | [underlined: Study Population] Adolescent males | • Strong-arming | | # (%) | p-value for racial diff. | # (%) | p-value for racial diff.
| Baseline: 729 | | [underlined: Inclusion criteria:] 7^th^ and 8^th^ grade boys enrolled in study in Spring 1988, over-sampled from high-crime neighborhoods or census tracts, using 9 waves covering 4.5 year. | • Rape | Rochester, NY | N=668 | <0.01 | N=606 | <0.0001
| Analysis: 562 (77%) | | [underlined: Exclusion criteria:] None | [underlined: Instrument used to measure outcome] | Total | 462 (69.2) | | 165 (27.2)
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | | [underlined: Main independent factor(s):] | • 37-item Self-Reported Delinquency Scale (SRD), improved version of the SRD scale used by National Youth Survey | African American | 315 (73.4) | | 121 (31.1)
| Age: Not specified | | • Age of onset of physical fighting, gang fighting or violent behavior. | [underlined: Type:] Rape, attack | Caucasian | 70 (58.8) | | 14 (12.6)
| Gender: 100% Male | | • Overt developmental pathway: | [underlined: Circumstance/Situational Context; Proactive/Reactive; Weapon used; Victim-offender relationship:] Not specified | Hispanic | 77 (64.2) | | 30 (27.5)
| Race: | | 1. Persisters: Those who engaged in any violent behavior at more than 1 annual assessment. | [underlined: Adverse Health Outcome:] Not studied | Fit in the overt developmental pathway:
| Rochester | | 2. Experimenters: Those who engaged in any violent behavior only once. | [underlined: Are mechanisms of violence theorized?] | Rochester, NY
| African Amer | 464 (63.6%) | 3. Nonfitters: Those whose ordering of reported behaviors was the inverse of that postulated by the overt development pathway. | Yes | [underlined: Persisters:] | [underlined: Steps 2 to 3] | [underlined: Step 2 only] | [underlined: Step 3 only] | [underlined: Total]
| Caucasian | 134 (18.4%) | [underlined: Instrument used to measure factors:] See Instruments used to measure outcome. | Overt pathway to boys' violent behavior stems from minor aggression (step 1) to physical fighting (step 2) to violent behavior (step 3). | | # (%) | # (%) | # (%) | # (%)
| Hispanic | 131 (18.0%) | [underlined: Covariates] | | Total | 130 (17.8) | 201 (27.6) | 2 ( 0.3) | 333 (45.7)
| Total | | Race | | Afr Amer | 95 (20.5) | 125 (26.9) | 2 ( 0.4) | 222 (47.8)
| African Amer | 916 (53.9%) | | | Caucasian | 12 ( 9.0) | 41 (30.6) | 0 ( 0.0) | 53 (39.6)
| Caucasian | 380 (22.4%) | | | Hispanic | 23 (17.6) | 35 (26.7) | 0 ( 0.0) | 58 (44.3)
| Hispanic | 357 (21.0%) | | | | [underlined: Exper.:] | [underlined: Excl./miss.:] | [underlined: Nonfitters:] | [underlined: No overt behav.:]
| Other | 46 ( 2.7%) | | | | # (%) | # (%) | # (%) | # (%)
| | | | | Total | 87 (11.9) | 35 ( 4.8) | 16 ( 2.2) | 258 (35.4)
| | | | | Afr Amer | 64 (13.8) | 23 ( 5.0) | 13 ( 2.8) | 142 (30.6)
| | | | | Caucasian | 13 ( 9.7) | 4 ( 3.0) | 0 ( 0.0) | 64 (47.8)
| | | | | Hispanic | 10 ( 7.6) | 8 ( 6.1) | 3 ( 2.3) | 52 (39.7)
| | | | | Entry into overt developmental pathway:
| | | | | Looking at proportion of Persisters and Experimenters entering at Step 2:
| | | | | | [underlined: Proportion (%)]
| | | | | Pittsburgh | 90
| | | | | Denver | 98
| | | | | Rochester | 98
| | | | | Comparing Persisters with Experimenters on the proportion entering at Step 2*:
| | | | | | [underlined: Odds ratios (95%CI)]
| | | | | Pittsburgh | 11.5 (3.7–35.7)
| | | | | Denver | Not reported
| | | | | Rochester | 10.1 (1.9–52.6)
| | | | | *Details on regression model not provided in study.
Record# | Study Quality | | | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | | Risk Factors Studied | | Implications
| Sample Size | | | Inclusion/Exclusion Criteria
7020 | [underlined: Study Design]: Prospective comparative cohort study | | | [underlined: Study Period (begin, end):] 1990-1999 | [underlined: Outcome (violence):] Adolescent aggression (provided by youth at time 3) | To determine whether exposure to marital violence in childhood predicts later adolescent aggression in different relationships.
McCloskey 2003 J Inter-personal. Violence | [underlined: Study Quality Score:] Fair (differences found between lost to follow-up and remaining cohort; analysis didn't take this into consideration). | | | [underlined: Place (city, state):] southwestern mid-size city | [underlined: Definition] | [underlined: Prevalence of Physical Aggression]
| [underlined: Sample size]: | | | [underlined: Study Setting:] Low-income community | Physical or threatened physical aggression towards same-sex peers, dating partners, and to parent | [underlined: Type] | [underlined: Boys (%)] | [underlined: Girls (%)] | [underlined: Chi-sq] | [underlined: p-value]
| No. of Mother-child pairs: | | | [underlined: Study Population:] Women from shelters and the community who had experienced partner abuse in the past year and their child; and comparison women without recent history of marital violence and their child | [underlined: Instrument used to measure outcome] | Same-sex peer | 77.4 | 58.0 | 12.70 | 0.001
| Time 1 | 1990 | 363 | [underlined: Inclusion criteria:] Mother-child pairs who completed interviews at all 3 time periods | • PI developed instrument | Dating partner | 11.1 | 20.3 | 4.61 | 0.03
| Time 2 | (1996-7) | 310 | [underlined: Exclusion criteria:] None specified | • Child Behavior Checklist | Child-to-parent | NA | NA | NA | ns
| Time 3 | (1998-9) | 296 | [underlined: Main independent factor(s): provided by mother] | • Conflict Tactics Scale modified by PI | [underlined: Physical Aggression by Childhood Exposure to Marital Violence]
| (82%) | | | • Childhood exposure to marital violence | [underlined: Type] | [underlined: Type] | [underlined: Exposed N (%)] | | [underlined: Unexposed N (%)]
| Marital violence | | 193 | • Sex | Physical or threatened physical aggression | Same-sex peer | 109 (73.6) | | 91 (62.0)
| Comparison group | | 170 | • Child age | [underlined: Circumstance/Situational Context; Proactive/Reactive; Weapon used]: not specified | Dating partner | 26 (17.7) | | 20 (13.8)
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | | | • Child depression symptoms | [underlined: Victim-offender relationship] | Child-to-parent | 16 (12.6) | | 19 (13.6)
| Age | | | • Child's capacity for empathy | • Peers | [underlined: Logistic Regressions PredictingPeer Aggression(N=295)]
| Time 1 | Mean | 9.2 | [underlined: Instrument used to measure factors:] | • Dating partners | [underlined: Factor] | β [underlined: (SE)] | [underlined: OR] | [underlined: 95% CI] | [underlined: p-value]
| | Range | 6 –12 | • Conflict Tactics Scale modified by PI | • Parents | • Regression 1
| Time 2 | Mean | 14.7 | • Catchment Epidemiologic Survey for Depression | [underlined: Adverse Health Outcome]: Not studied | Marital violence | 0.32 (0.10) | 1.37 | 1.12–1.68 | <0.01
| Time 3 | Mean | 16.4 | • PI developed instrument | [underlined: Are mechanisms of violence theorized?] | Child's sex (girl) | -0.72 (0.27) | 0.41 | 0.24–0.69 | <0.001
| Gender | Not specified | | [underlined: Covariates] | Yes | Older than 18 | 0.62 (0.29) | 1.87 | 1.05–3.30 | <0.05
| Race | | | • Child's empathy | Depression and empathy are plausible mediators in the cycle of violence. | • Regression 2
| African American | | 4.7% | • Child's depression | | Marital violence | 0.25 (0.11) | 1.28 | 1.04–1.58 | <0.05
| Anglo European | | 53.7% | | | Child's sex (girl) | -1.02 (0.28) | 0.36 | 0.21–0.62 | <0.001
| Asian American | | 0.7% | | | Older than 18 | 0.62 (0.30) | 1.86 | 1.04–3.36 | <0.05
| Hispanic | | 35.8% | | | Depression | 1.22(0.34) | 3.40 | 1.74–6.63 | <0.001
| Native American | | 4.4% | | | • Regression 3
| Other | | 0.7% | | | Marital violence | 0.31 (0.11) | 1.36 | 1.11–1.67 | <0.01
| | | | | | Child's sex (girl) | -0.72 (0.28) | 0.49 | 0.28–0.85 | <0.05
| | | | | | Older than 18 | 0.70 (0.30) | 2.02 | 1.12–3.36 | <0.01
| | | | | | Empathy | -0.65 (0.28) | 0.52 | 1.12–3.63 | <0.01
| | | | | | [underlined: Logistic Regressions PredictingDating Aggression(N=292)]
| | | | | | [underlined: Factor] | β [underlined: (SE)] | [underlined: OR] | [underlined: 95% CI] | [underlined: p-value]
| | | | | | • Regression 1
| | | | | | Marital violence | -0.07 (0.13) | 0.94 | 0.73 – 4.20 | ns
| | | | | | Child's sex (girl) | -2.28 (1.48) | 0.10 | 0.006 – 1.86 | ns
| | | | | | Older than 18 | 1.35 (0.37) | 3.86 | 1.87 – 7.97 | <0.001
| | | | | | Depression | 0.18 (0.67) | 1.19 | 0.32 – 4.44 | ns
| | | | | | Depression x Sex | 1.74 (0.83) | 5.70 | 1.12 –28.93 | <0.05
| | | | | | • Regression 2
| | | | | | Marital violence | 0.03 (0.12) | 1.04 | 0.82 – 1.30 | ns
| | | | | | Child's sex (girl) | 1.18 (0.39) | 3.26 | 1.54 – 6.94 | <0.01
| | | | | | Older than 18 | 1.37 (0.36) | 3.92 | 1.95 – 7.85 | <0.001
| | | | | | Empathy | -0.94 (0.32) | 0.39 | 0.21 – 0.73 | <0.01
| | | | | | [underlined: Logistic Regressions PredictingChild-to-ParentAggression (N=267)]
| | | | | | [underlined: Factor] | β [underlined: (SE)] | [underlined: OR] | [underlined: 95% CI] | [underlined: p-value]
| | | | | | • Regression 1
| | | | | | Marital violence | -0.28 (0.21) | 0.76 | 0.50–1.15 | ns
| | | | | | Child's sex (girl) | 0.13 (0.38) | 1.14 | 0.54–2.42 | ns
| | | | | | Older than 18 | -0.09 (0.58) | 0.91 | 0.29–2.82 | ns
| | | | | | Marital violence x Older than 18 | 0.48 (0.28) | 1.62 | 0.94–2.78 | <0.10
| | | | | | Depression | 0.72 (0.39) | 2.05 | 0.96–4.40 | <0.10
| | | | | | • Regression 2
| | | | | | Marital violence | 0.23 (0.21) | 0.80 | 0.53–1.20 | ns
| | | | | | Child's sex (girl) | 0.30 (0.40) | 1.35 | 0.62–2.96 | ns
| | | | | | Older than 18 | -0.02 (0.57) | 0.98 | 0.32–3.00 | ns
| | | | | | Marital violence x Older than 18 | 0.49 (0.28) | 1.63 | 0.95–2.79 | ns
| | | | | | Empathy | -0.38 (0.38) | 0.68 | 0.33–1.43 | ns
Record # | Study Quality | | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | Risk Factors Studied | | Implications
| Sample Size | | Inclusion/Exclusion Criteria
7114 | [underlined: Study Design]: Prospective cohort study (part of an ongoing longitudinal study of the development of antisocial behavior from childhood to young adulthood) | | [underlined: Study Period (begin, end):] 1984-1993 | [underlined: Outcome (violence):] Serious offenses scale at Grade 6, 8 and 10 over the past year. | [underlined: To examine peer rejection and aggression as predictors of the severity and type of adolescent delinquency]
Miller-Johnson 1999 J Emo-tional & Behav Disorders | [underlined: Study Quality Score:] Poor (attrition rate > 20%) | | [underlined: Place (city, state):] Durham, NC | [underlined: Definition] | [underlined: Serious offense rates by Sex]
[Longitudinal study description in Coie et al., 1992 and Coie et al., 1995] | [underlined: Sample size]: | | [underlined: Study Setting:] Public school system | Part of the FBI's measure of serious crime and include felony, theft, felony assault, robbery | | [underlined: Boys (%)] | [underlined: Girls (%)] | [underlined: Chi-sq] | [underlined: p-value]
| 3rd grade participants 1749 | | [underlined: Study Population:] A subsample of 3^rd^ graders from 12 elementary schools in the local district who participated in follow-up at 2-year intervals across adolescence, beginning in 6th grade. | [underlined: Instrument used to measure outcome] | Grade 6 | 30.1 | 15.9 | 9.34 | <0.01
| 6th grade particpants 622 | | [underlined: Inclusion criteria:] Study participation in grades 6, 8, and 10 | National Youth Survey | Grade 8 | 30.7 | 15.2 | 11.01 | <0.01
| Completed followup: 327 (53%) | | [underlined: Exclusion criteria:] Students who were not African American | [underlined: Type] | Grade 10 | 27.6 | 21.3 | NA | ns
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | | [underlined: Main independent factor(s):] | Not specified | [underlined: Log-linear analyses examining 3] ^[underlined: rd]^ [underlined: grade rejection and aggression as predictors of serious scales]
| [underlined: Age] | | • Measures of peer social status | [underlined: Circumstance/Situational Context] | | | For Boys | For Girls
| Baseline: | Grade 3 | • Measures of social behavior and aggression | Not specified | | | [underlined: Chi-sq (p-value)] | [underlined: Chi-sq (p-value]
| Follow-up: | Grades 6 | [underlined: Instrument used to measure factors:] PI developed instrument | [underlined: Proactive/Reactive] | Aggression | | 7.56 (<0.01) | 4.02 (<0.05)
| | Grade 8 and Grade 10 | [underlined: Covariates] | Not specified | Rejection | | ns | ns
| [underlined: Gender] 164 (50.2%) male | | • Gender | [underlined: Weapon used] | Rejection × Aggression | | 7.73 (<0.01) | ns
| [underlined: Race] 100% African Amer | | | Not specified | [underlined: Log-linear analyses of Rejection and Aggression as predictors of minor assault, felony assault, and robbery]
| | | | [underlined: Victim-offender relationship] | Boys | Minor Assault | Felony Assault | Robbery
| | | | Not specified | Risk Factor | OR (p-value) | OR (p-value) | OR (p-value)
| | | | [underlined: Adverse Health Outcome]: Not studied | Rejection | ----- (ns) | 1.16 (<.05) | ------ (ns)
| | | | [underlined: Are mechanisms of violence theorized?] | Aggression | 1.22 (<.01) | 1.22 (<.01) | 0.96 (<0.01)
| | | | Yes | Interaction | ------ (ns) | ----- (<.01) | ------ (ns)
| | | | No | Girls | Minor Assault | Felony Assault | Robbery
| | | | [underlined: If yes, state the theory:] | Risk Factor | OR (p-value) | OR (p-value) | OR (p-value)
| | | | | Rejection | 1.10 (<0.01) | ----- (ns) | ----- (ns)
| | | | | Aggression | ----- (ns) | ----- (ns) | ----- (ns)
| | | | | Interaction | ----- (ns) | ----- (ns) | ----- (ns)
Record # | Study Quality | | | Study Characteristic | Outcome (Violence) Definition and Characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | | Risk Facros Studied | | Implications
| Sample Size | | | Inclusion/Exclusion Criteria
11065 | [underlined: Study Design]: Prospective comparative cohort | | | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] Fighting | [underlined: Violence Outcome]
McNulty 2003 Justice Quarterly | [underlined: Study Quality Score:] Poor (attrition >20%) | | | 1988 (wave 1) | [underlined: Definition] | To specify a contextual model of differences in violence between youths who are white and those from five racial-ethnic groups.
| [underlined: Sample size]: | | | 1990 (wave 2) | Number of times respondents had been in a physical fight at or on the way to or from school over the previous half year (once or more) | [underlined: Logistic regression of fighting (variables entered separately)]
| Target: 25,000 | | | 1992 (wave 3) | [underlined: Instrument used to measure outcome] | Variable | 1 | 2 | 3 | 4
| 3 waves: 16,489 (66%) | | | [underlined: Place (city, state):] U.S. | Survey | Race-Ethnicity
| Analysis:14,358 (57%) | | | [underlined: Study Setting:] School from 2,988 locales | [underlined: Type] | White (ref)
| [underlined: Age] Not specified | | | [underlined: Study Population:] 25 8^th^ graders each from 1000 middle schools followed to 1992 | Fights | Asian | .08 | .07 | .07 | .02
| [underlined: Gender] | | | [underlined: Inclusion criteria:] 8^th^ graders | [underlined: Circumstance/Situational Context] | Am. Indian. | .95** | .76* | .85** | .94**
| Male | 50% | | [underlined: Exclusion criteria:] Missing values on violence outcome but missing values on explanatory measures were imputed. | To/From School | Black | .51** | .32 | .42** | .48**
| [underlined: Race] | Mean | SD | [underlined: Main independent factor(s):] | [underlined: Proactive/Reactive, Weapon used, Victim-offender relationship] | Latino | .41** | .32* | .21 | .37**
| Asian | 4% | 19% | Race-ethnicity | Not specified | Other | .02 | -.03 | -.05 | -0.2
| Am Indian | 1% | 99% | Community-level measures | [underlined: Adverse Health Outcome]: Not studied | Community Context
| Black | 12% | 33% | - Concentrated disadvantage composite index of | [underlined: Are mechanisms of violence theorized?] | % urban | | -.00
| Latino | 9% | 29% | • % persons with 1989 incomes below poverty threshold | Yes | % owner | | -.00
| Other | 1% | 9% | • % households headed by women | [underlined: If yes, state the theory:] Racial-ethnic differences in violence should disappear when variation in structural components, family well-being and social capital is adequately controlled. | % aged 15–24 | | -.01
| White | 83% | ---- | • % civilian labor force who are unemployed | | Concentrated disadv. | | .04**
| | | | • % population African American | | Family Well-being
| | | | Measures of Family Well-being | | Live with both parents | | | -.04
| | | | • family structure: two-biological-parent families, single-parent/stepparent families | | Family income | | | -.00
| | | | • family income | | Welfare receipt | | | .68
| | | | • welfare receipt | | Parents' Education
| | | | • parental education | | Less than High School (ref)
| | | | Measures of Social Capital | | High school degree | | | -.45**
| | | | • parental interaction with other parents (Parents know friends' parents) | | Some college | | | -.47**
| | | | • parental interaction at school (how often discuss things with other parents at school) | | College degree | | | -.54**
| | | | • adolescent interaction with adults (time adolescent spends talking or doing things with parents) | | Professional degree | | | -1.10**
| | | | [underlined: Instrument used to measure factors:] | | Social Capital
| | | | • Race-ethnicity and individual data: Survey | | Parents Know Friends' parents
| | | | • Community-level measures: derived from zip code-level data from 1990 U.S. Census | | No parents (ref)
| | | | • Parent well-being data from parent survey | | Some parents | | | | -.25**
| | | | [underlined: Covariates] | | Many parents | | | | -.29**
| | | | Individual controls | | Adolescent's Interaction with Adults
| | | | • Gender | | Rare/never (ref)
| | | | • Moved in the past two years | | Sometimes | | | | -.30**
| | | | • Prior fighting | | Frequently | | | | -.20**
| | | | • Perception of fighting (often/sometimes okay vs. rarely/never okay to fight) | | Parents' Interaction at School | | | | -.01
| | | | • School achievement (grades in English, math, history, science) | | Constant | -1.76 | -1.58 | -1.37 | -1.50
| | | | • Alcohol/drug use in the past 30 days | | Pseudo R-square | .19 | .19 | .19 | .19
| | | | Community | | N | | 14,358
| | | | • % housing units owner occupied | | Controlled for sex, moved, prior fighting, perception is okay to fight, school grades, drug use
| | | | • % population in crime-prone ages (15–24) | | [underlined: Logistic regression of fighting (variables entered sequentially)]
| | | | • % urban | | Variable | 1 | 2 | 3 | 4 | 5
| | | | | | Race-Ethnicity
| | | | | | White (ref)
| | | | | | Asian | .07 | .03 | -.02 | .01 | .01
| | | | | | Am. Indian | .76* | .72* | .73* | .76* | .84**
| | | | | | Black | .32 | .27 | .25 | .30 | .39**
| | | | | | Latino | .32* | .15 | .11 | .28* | .17
| | | | | | Other | -.03 | -.08 | -.11 | -.06 | -.08
| | | | | | Community Context
| | | | | | % urban | -.00 | -.00 | -.00 | -.00
| | | | | | % owner | -.00 | -.00 | -.00 | -.00
| | | | | | % aged 15–24 | -.01 | -.01 | -.01 | -.01
| | | | | | Concentrated disadv. | .04** | .03 | .03 | .03*
| | | | | | Family Well-being
| | | | | | Live with both parents | | -.03 | -.03 | | -.04
| | | | | | Family income | | -.00 | -.00 | | -.00
| | | | | | Welfare receipt | | .70 | .70 | | .68
| | | | | | Parents' Education
| | | | | | Less than High School (ref)
| | | | | | High school degree | | -.42** | -.42** | | -.49**
| | | | | | Some college | | -.44** | -.43** | | -.46**
| | | | | | College degree | | -.51** | -.51** | | -.54**
| | | | | | Professional degree | | -1.11** | -1.09** | | -1.08**
| | | | | | Social Capital
| | | | | | Parents Know Friends' parents
| | | | | | No parents (ref)
| | | | | | Some parents | | | -.24* | -.25* | -.25*
| | | | | | Many parents | | | -.26* | -.29** | -.26*
| | | | | | Adolescent's Interaction with Adults
| | | | | | Rarely/never (ref)
| | | | | | Sometimes | | | -.28** | -.28** | -.29**
| | | | | | Frequently | | | -.21* | -.20* | -.22*
| | | | | | Parents' Interaction at School | | | -.01 | -.01 | -.01
| | | | | | Constant | -1.58 | -1.20 | -.97 | -1.31 | -1.13
| | | | | | Pseudo R-square | .19 | .20 | .20 | .19 | .20
| | | | | | N | | 14,358
| | | | | | Controlled for gender, moved, prior fighting, perception okay to fight, school grades, drug use
| | | | | | **p<.01, *p<.05 (two-tailed test)
Record # | Study Quality | | | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | | Risk Factors Studied | | Implications
| Sample Size | | | Inclusion/Exclusion Criteria
11087 | [underlined: Study Design]: Prospective comparative cohort, although data is from an intervention study. | | | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] physical aggression | [underlined: Violence Outcome]
O'Leary 2003 J Clinical Child and Adolescent Psychology | [underlined: Study Quality Score:] Unknown (attrition rate not reported). | | | Beginning of Spring, 1995 | [underlined: Definition] | Objectives were the following:
| [underlined: Sample size]: 206 (a subset of 2,320 students included in a psychometric study) | | | End of Fall, 1996 | Ever threw something at, kicked, bit, hit, or restrained partner. | 1. Examine stability of dating aggression.
| [underlined: Age]: | | | [underlined: Place (city, state):] Seven Suffolk County, NY | [underlined: Instrument used to measure outcome]: mCTS (Modified Conflict Tactics Scale) | 2. Determine whether psychological victimization at baseline predicted physical aggression (at baseline and followup)
| Boys= 16.51 years ± 0.70 | | | [underlined: Study Setting:] high schools | [underlined: The following not specified:] Type, Circumstance/Situational Context, Proactive/Reactive, Weapon used, adverse health outcome. | [underlined: Correlations between physical aggression and other study variables :]
| Girls= 16.40 years ± 0.73 | | | [underlined: Study Population:] Ethnically and racially diverse sample of high school students enrolled in a mandatory health education class. | [underlined: Victim-offender relationship] in a romantic relationship. | | Physical aggression
| [underlined: Gender]: 86 boys, 120 girls | | | [underlined: Inclusion criteria:] | [underlined: Are mechanisms of violence theorized?] | | Follow-up T2
| [underlined: Race:] | | | Student consent and passive parental consent | Yes | Variable | Boys | Girls
| | Boys% | Girls% | Students reported that they were in the same relationship at baseline and 14-week followup. | [underlined: If yes, state the theory:] The notion of male dominance within a patriarchical marriage (Dobash & Dobash, 1979) | Verbal Aggression | .45** | .35**
| White: | 69.8 | 59.2 | [underlined: Exclusion criteria:] See inclusion criteria. | The background-situational model of dating aggression (Riggs & O'Leary 1989Riggs & O'Leary 1996). | Jealous Aggression | .25* | .21*
| Black: | 12.8 | 17.5 | [underlined: Main independent factors] | | Controlling Aggression | .41** | .22*
| Latino: | 7.0 | 9.2 | 1. Psychological aggression and victimization (verbal, jealous behavior, controlling behavior) | | Verbal Victimization | .61** | .43**
| Asian: | 4.7 | 3.3 | 2. Physical victimization | | Jealous Victimization | .39** | .16
| Mixed: | 5.8 | 8.3 | [underlined: Instrument used to measure factors:] | | Controlling Victimization | .42** | .33**
| Other: | 0 | 2.5 | 1. Verbal= mCTS | | Physical Aggression T1 | .55** | .57**
| | | | Jealous and controlling behaviors= Control and Jealous scales from the Psychological Maltreatment of Women Inventory | | Physical Victimization T1 | .77** | .67**
| | | | 2. mCTS | | *p< .05; **p< .001.
| | | | [underlined: Covariates] | | [underlined: STRUCTURAL EQUATION MODEL FINDINGS:]
| | | | None specified. | | [underlined: Regression Coefficient (from T1 to T2)]
| | | | | | | Boys | Girls
| | | | | | Own psych aggression T1→
| | | | | | Own phys aggression T1 | .50** | .58**
| | | | | | Own phys. aggression T1→
| | | | | | Own phys. aggression T2 | -.17 | .13
| | | | | | Own phys. aggression T1→
| | | | | | Partner's phys aggression T2 | .53** | .54**
| | | | | | Partner's psych aggression T1→
| | | | | | Partner's phys aggression T1 | .72** | .61**
| | | | | | Partner's phys aggression T1→
| | | | | | Own phys aggression T2 | .77** | .57**
| | | | | | Partner's phys aggression T1→
| | | | | | Partner's phys aggression T2 | .23 | .20
Record# | Study Quality | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | Risk Factors Studied | | Implications
| Sample Size | Inclusion/Exclusion Criteria
7453 | [underlined: Study Design]: Prospective cohort study (from the Collaborative Perinatal Project (CPP), a nationwide study of genetic, biological, and environmental influences on child development (Niswander & Gordon, 1972) | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] Criminal violent offending between 7 and 22 | [underlined: Violence Outcome]
Piquero 1999 Studies on Crime and Crime Prevention | [underlined: Study Quality Score:] Unsure (attrition rate is not clear.) | Initial cohort: 1959-1962 | [underlined: Definition] | To evaluate the impact of pre/perinatal disturbances and disadvantaged familial environment in predicting criminal violent offending.
| [underlined: Sample size]: | Follow-up: until age 22 | Violent/injury offenses: | [underlined: Prevalence of violent offending]
| Original cohort: 2,958 | [underlined: Place (city, state):] Philadelphia, PA | • murder | | Both sexes | Male | Female | p
| Study cohort: 987 (33%) | [underlined: Study Setting:] Recruited from Pennsylvania Hospital | • assault with intent to kill | Number (%) | 38 (4.4%) | 33 (7.8%) | 5 (1.1%) | <.001
| Analysis: 867 (88%) | [underlined: Study Population:] High risk inner city sample of children born to women who attended Pennsylvania Hospital between 1959 and 1962 | • aggravated assault | [underlined: Logistic regression predicting violent offending (n-867)]
| The study cohort was taken from the ICPSR secondary data analysis archive assembled by Denno (1990). | [underlined: Inclusion criteria]: see above | • simple assault | Factor | | β | [underlined: SE] | [underlined: p-value]
| [underlined: Age]: Followed from birth to late adolescence | [underlined: Exclusion criteria:] | • rape | Pre/perinatal disturbances | | 0.0717 | 0.3521 | ns
| [underlined: Gender]: | • Unregistered emergency deliveries | • robbery with injury | Disadv. familial environ. | | 0.0918 | 0.0647 | ns
| 425 (49%) male | • Women planning to deliver elsewhere | • any other offense that involved injury to the victim | Biosocial interaction* | | 0.2484 | 0.1293 | <0.05
| 442 (51%) female | [underlined: Main independent factor(s):] | [underlined: Instrument used to measure outcome] | Sex | | -2.0635 | 0.4874 | <0.05
| [underlined: Race]: | • Pre/perinatal disturbances | • Official Philadelphia Police Department records | Constant | | -0.4489 | 0.5799 | ns
| African Amer: 100% | • Disadvantaged familial environment | [underlined: Type:] see above | -2 Log Likelihood | | 280.585
| | • Biosocial interaction of pre/perinatal disturbances and disadvantaged familial environment | [underlined: Circumstance/Situational Context; Proactive/Reactive; Weapon used; Victim-offender relationship:] Not specified | Chi-square/df (p-value) | | 31.411/4 (<0.05)
| | [underlined: Instrument used to measure factors:] | [underlined: Adverse Health Outcome]: Not studied | *Biosocial interaction modeled as a continuous variable.
| | • PI of Collaborative Perinatal Project developed | [underlined: Are mechanisms of violence theorized?] | [underlined: Logistic regression of 4 category biosocial interaction on violent offending (n=867)]
| | [underlined: Covariates] | Yes | Factor | | β | [underlined: SE] | [underlined: p-value]
| | • Sex | Biosocial interaction hypothesis: Pre/perinatal disturbances, when combined with disadvantaged familial environment at age seven, increase the chances of criminal offending during early adulthood. | Biosocial interaction* | | | | ns
| | | | Disadvantaged familial envir. | Pre/perinatal disturbances
| | | | yes | no | -0.1874 | 0.5800 | ns
| | | | no | Yes | -0.2076 | 0.4097 | ns
| | | | yes | yes | 0.8874 | 0.4672 | 0.057
| | | | Sex | | -2.048 | 0.4874 | <0.05
| | | | Constant | | -0.4555 | 0.6103 | ns
| | | | -2 Log Likelihood | | 281.873
| | | | Chi-square/df (p-value) | | 30.123/4 (<0.05)
| | | | *Biosocial interaction modeled as a categorical variable: 0=no in both factors; 1=weak familial environment and no pre/perinatal disturbance; 2=pre/perinatal disturbance and no weak familial environment, 3=both present. Reference group includes those who did not have a weak familial environment and no pre/perinatal disturbance.
Record # | Study Quality | | | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | | Risk Factors Studied | | Implications
| Sample Size | | | Inclusion/Exclusion Criteria
1029 | [underlined: Study Design]: Prospective comparative cohort study (a National Institute of Justice funded project) | | | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Rivera 1990 Violence and Victims | [underlined: Study Quality Score:] Fair (attrition rate not known) | | | Initial cohorts: 1967 thru 1971; | [underlined: Outcome measure] Violent criminal behavior as a juvenile (less than 18 years of age) | To examine the role of childhood abuse and neglect in violent offending.
[Findings on juveniles were also reported in a later publication by Maxfield in 1996, ID#437]. | [underlined: Sample size]: | | | Follow-up 1987 and 1988 | [underlined: Definition] | [underlined: Percentage of violent offenders]
| Victimized Group: | | 908 | [underlined: Place (city, state):] Midwest | Arrests for: | | [underlined: Victimized] | [underlined: Controls] | | [underlined: Chi-sq] | [underlined: p-value]
| Control Group: | | 667 | [underlined: Study Setting:] Metropolitan area | • murder/attempted murder | All | 4.2 | 2.8 | | 1.97 | ns
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | | | [underlined: Study Population:] All cases of physical and sexual abuse and neglect processed in the county juvenile court and matched control children. | • manslaughter/involuntary manslaughter/reckless homicide | Male | 6.5 | 5.4 | | 0.45 | ns
| [underlined: Victimzed Group (n=908)] | | | [underlined: Inclusion criteria:] | • rape/sodomy | Female | 1.9 | 0.3 | | 2.79 | <0.10
| Age | Mean/SD | 25.69/3.53 | Victimized group: All cases of physical and sexual abuse and neglect processed in the county juvenile court | • robbery/robbery with injury | White | 2.0 | 1.6 | | 0.18 | ns
| | Range | 16–32 | Control group: Children matched to controls on sex, race, date of birth, and hospital of birth or under school age or class. | • assault/assault and battery/aggravated assault | Black | 9.2 | 5.2 | | 3.09 | <0.10
| Gender | 49% Male | | [underlined: Exclusion criteria:] | • battery/battery with injury | [underlined: Logistic regression for violent arrest as a juvenile]
| Race | 67% White | | Victimized group: Children who were not less than 11 years of age at the time of abuse or neglect | [underlined: Instrument used to measure outcome] | [underlined: Factor] | | [underlined: Coefficent (SE)] | | [underlined: Coeff greater than 2x SE?]
| | 31% Black | | Control Group: Any evidence that the child had been abused or neglected | | Male | | 1.67 (0.35) | | yes
| [underlined: Control Group (n=667)] | | | [underlined: Main independent factor(s):] Physical abuse, sexual abuse, and neglect | • Juvenile probation department files | Black | | -1.51 (0.29) | | yes
| Age | Mean/SD | 25.76/3.53 | [underlined: Instrument used to measure factors:] Juvenile court and juvenile probation department files | [underlined: Type, Circumstance/Situational Context, Proactive/Reactive, Weapon used, and Victim-offender relationship:] Not specified | Age (in years) | | 0.02 (0.04) | | no
| | Range | 16–33 | [underlined: Other risk factors] | [underlined: Adverse Health Outcome]: Not studied | Victimized | | 0.53 (0.29) | | no
| Gender | Not specified | | Sex | [underlined: Are mechanisms of violence theorized?] | Constant | | -4.88 (1.27) | | no
| (“equal numbers of males and females”) | | | Race | No | [underlined: Chronicity of violent offending]
| Race | 65% White | | | | | Arrests for violent crime (%)
| | 35% Black | | | | | [underlined: None] | [underlined: One] | [underlined: 2 or more] | [underlined: Chi-sq] | [underlined: p-value]
| | | | | | Victimized | 95.8 | 3.0 | 1.2 | 5.86 | 0.053
| | | | | | Controls | 97.2 | 2.7 | 0.1
Record # | Study Quality | | Study Characteristic | Outcome (violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | Risk Factors Studied | | Implications
| Sample Size | | Inclusion/Exclusion Criteria
7662 | [underlined: Study Design]: Prospective, cohort study (taken from the first 5 years of the National Youth Survey (NYS)) | | [underlined: Study Period (begin, end):] 1976-1980 | [underlined: Outcome (violence):] | To test an integrated theory of illegal behavior for non-profitable illegal violent behavior.
Roitberg 1995 Studies on Crime and Crime Prevention | [underlined: Study Quality Score: Unsure] | | [underlined: Place (city, state):] United States | [underlined: Outcome measure] | [underlined: Standardized regression coefficients for FREQUENCY of felony assault:]
| • Poor if participation rate is considered | | [underlined: Study Setting:] Household-based | Felony assault scale, 2 measures: | •Model 1 (no time-lagged endogenous variable)
| • Good if participation rate is not considered | | [underlined: Study Population:] American youths aged 11–17 in 1976 | • annual frequency | | 1977 | | 1978 | | 1979 | | 1980
| [underlined: Sample size:] | | [underlined: Inclusion criteria:] Unmarried | • prevalence during year (yes or no) | Factor | β | p-val | β | p-val | β | p-val | β | p-val
| Initial | 1725 | [underlined: Exclusion criteria:] None | [underlined: Definition] | DPGB | 0.323 | le 0.01 | 0.232 | le 0.01 | 0.415 | le 0.01 | 0.260 | le 0.01
| (75% of original) | | [underlined: Main independent factor(s): Measured at or prior to outcome:] | • Aggravated assault | Belief | 0.072 | le 0.05 | -0.080 | le 0.01 | 0.057 | ns | -0.051 | ns
| Actual | 1494 | • Delinquent peer group bonding (DPGB) | • Gang fighting | Family involve | -0.045 | ns | 0.007 | ns | -0.009 | ns | -0.008 | ns
| (87% of initial) | | • Belief that it is wrong to violate the law | • Sexual assault | School involve. | 0.035 | ns | -0.030 | ns | -0.047 | ns | 0.055 | ns
| [underlined: Age] : Mean Not specified | | • Family involvement | [underlined: Instrument used to measure outcome] | Family normless | 0.024 | ns | -0.027 | ns | -0.101 | le 0.01 | -0.017 | ns
| Baseline: Range11–17 | | • School involvement | National Youth Survey | School normless | 0.005 | ns | 0.046 | ns | 0.103 | le 0.01 | -0.011 | ns
| Outcome: Range 15–21 | | • Family normlessness | [underlined: Type]: see above | School strain (-) | -0.049 | ns | -0.087 | le 0.01 | -0.041 | ns | -0.042 | ns
| [underlined: Gender]: Not specified | | • School normlessness | [underlined: Circumstance/Situational Context; Proactive/Reactive; Weapon used; Victim-offender relationship:] Not specified | Job strain (-) | 0.018 | ns | -0.004 ns | ns | -0.005 ns | ns | 0.004 | ns
| [underlined: Race:] Not specified | | • Occupational strain | [underlined: Adverse Health Outcome:] Not studied | Rural residence | -0.023 | ns | -0.033 | ns | -0.040 | ns | -0.035 | ns
| | | • School stain | [underlined: Are mechanisms of violence theorized?] | SES (high) | -0.078 | le 0.01 | -0.037 | ns | -0.037 | ns | -0.036 | ns
| | | • Sex | Yes | \|Age- 15\| | -0.029 | ns | 0.079 | Ns | 0.055 | Ns | 0.050 | ns
| | | • Age | [underlined: If yes, state the theory:] | Avg parity | -0.043 | ns | 0.053 | ns | 0.033 | ns | -0.014 | ns
| | | • Race | Integrated theory: | Gender (female) | -0.102 | le 0.01 | -0.082 | le 0.01 | -0.040 | ns | -0.058 | ns
| | | • Parents' socioeconomic status | • Social and demographic background variables influence perceived and objecticve opportunities to attain academic, occupational and other goals, and may be associatead with differences in socialization. | Race (nonwhite) | 0.048 | ns | 0.024 | ns | 0.084 | le 0.01 | 0.011 | ns
| | | • Average parity, family size at time of birth | • Combines elements of strain, social control, and social learning theories. | • Model 2 (with the time-lagged endogenous variable)
| | | • Urban, suburban, or rural residence | • Delinquent peer group bonding leads to illegal behavior. | | 1977 | | 1978 | | 1979 | | 1980
| | | [underlined: Instrument used to measure factors:] National Youth Survey | | Factor | β | p-val | β | p-val | β | p-val | β | p-val
| | | [underlined: Covariates] | | DPGB | 0.289 | le 0.01 | 0.172 | le 0.01 | 0.371 | le 0.01 | 0.175 | le 0.01
| | | None | | Belief | 0.098 | le 0.05 | -0.022 | ns | 0.077 | le 0.05 | 0.012 | ns
| | | | | Family involv. | -0.039 | ns | -0.013 | ns | 0.008 | ns | -0.004 | ns
| | | | | School involv. | 0.050 | le 0.05 | -0.009 | ns | -0.046 | ns | -0.001 | ns
| | | | | Family normless | 0.009 | ns | 0.018 | ns | -0.089 | le 0.01 | 0.031 | ns
| | | | | School normless | -0.019 | ns | 0.032 | ns | 0.062 | ns | -0.046 | ns
| | | | | School strain (-) | -0.018 | ns | -0.053 | ns | -0.019 | ns | 0.008 | ns
| | | | | Job strain (-) | 0.016 | ns | 0.000 | ns | -0.001 | ns | -0.004 | ns
| | | | | Rural residence | 0.006 | ns | -0.022 | ns | -0.039 | ns | 0.007 | ns
| | | | | SES (high) | -0.059 | le 0.05 | -0.010 | ns | -0.022 | ns | -0.038 | ns
| | | | | \|Age- 15\| | -0.038 | ns | 0.096 | ns | 0.021 | ns | 0.016 | ns
| | | | | Avg parity | -0.022 | ns | 0.077 | ns | 0.002 | ns | -0.022 | ns
| | | | | Gender (female) | -0.060 | le 0.01 | -0.049 | le 0.05 | -0.016 | ns | -0.052 | ns
| | | | | Race (nonwhite) | 0.040 | ns | 0.004 | ns | 0.074 | le 0.01 | 0.047 | ns
| | | | | Prior offending | 0.328 | le 0.01 | 0.411 | le 0.01 | 0.342 | le 0.01 | 0.511 | le 0.01
| | | | | [underlined: Standardized regression coefficients for PREVALENCE of felony assault]
| | | | | • Model 1 (no time-lagged endogenous variable)
| | | | | | 1977 | | 1978 | | 1979 | | 1980
| | | | | Factor | β | p-val | β | p-val | β | p-val | β | p-val
| | | | | DPGB | 0.304 | le 0.01 | 0.220 | le 0.01 | 0.361 | le 0.01 | 0.256 | le 0.01
| | | | | Belief | 0.078 | ns | -0.150 | le 0.01 | 0.028 | ns | -0.128 | ns
| | | | | Family involv. | 0.109 | le 0.05 | 0.030 | ns | -0.042 | ns | -0.071 | ns
| | | | | School involv. | 0.077 | ns | 0.101 | ns | 0.161 | le 0.05 | -0.106 | ns
| | | | | Family normless | 0.093 | ns | 0.010 | ns | 0.167 | ns | 0.087 | ns
| | | | | School normless | 0.050 | ns | 0.051 | ns | 0.252 | le 0.01 | 0.093 | ns
| | | | | School strain (-) | -0.164 | le 0.01 | -0.153 | le 0.01 | -0.109 | ns | -0.122 | ns
| | | | | Job strain (-) | 0.016 | ns | 0.034 | ns | 0.008 | ns | 0.010 | ns
| | | | | Rural residence | 0.081 | ns | 0.026 | ns | -0.039 | ns | 0.082 | ns
| | | | | SES (high) | -0.183 | le 0.01 | 0.138 | le 0.05 | -0.074 | ns | 0.000 | ns
| | | | | \|Age- 15\| | -0.007 | ns | 0.168 | ns | 0.288 | ns | 0.093 | ns
| | | | | Avg parity | -0.120 | ns | 0.138 | ns | 0.190 | ns | -0.032 | ns
| | | | | Gender (female) | -0.275 | le 0.01 | 0.235 | le 0.01 | -0.150 | le 0.05 | 0.224 | le 0.01
| | | | | Race (nonwhite) | 0.070 | ns | 0.053 | ns | 0.161 | le 0.01 | 0.065 | ns
| | | | | • Model 2 (with the time-lagged endogenous variable)
| | | | | | 1977 | | 1978 | | 1979 | | 1980
| | | | | Factor | β | p-val | β | p-val | β | p-val | β | p-val
| | | | | DPGB | 0.301 | le 0.01 | 0.189 | le 0.01 | 0.391 | le 0.01 | 0.224 | le 0.01
| | | | | Belief | 0.121 | le 0.05 | -0.101 | ns | 0.012 | le 0.05 | 0.053 | ns
| | | | | Family involv | -0.102 | Ns | 0.055 | ns | 0.004 | ns | -0.067 | ns
| | | | | School involv | 0.112 | le 0.05 | 0.067 | ns | -0.169 | le 0.05 | 0.011 | ns
| | | | | Family normless | 0.061 | ns | 0.007 | ns | -0.157 | ns | -0.066 | ns
| | | | | School normless | 0.008 | ns | 0.035 | ns | 0.196 | le 0.05 | -0.011 | ns
| | | | | School strain (-) | -0.126 | le 0.05 | -0.166 | ns | -0.058 | ns | -0.066 | ns
| | | | | Job strain (-) | 0.015 | ns | 0.033 | ns | 0.025 | ns | -0.002 | ns
| | | | | Rural residence | -0.043 | ns | -0.001 | ns | -0.056 | ns | -0.058 | ns
| | | | | SES (high) | -0.192 | le 0.01 | -0.083 | ns | -0.046 | ns | -0.000 | ns
| | | | | \|Age- 15\| | -0.022 | ns | 0.234 | ns | 0.282 | ns | -0.004 | ns
| | | | | Avg parity | -0.072 | ns | 0.244 | ns | 0.160 | ns | -0.097 | ns
| | | | | Gender (female) | -0.209 | le 0.01 | -0.184 | le 0.01 | -0.090 | ns | -0.221 | le 0.01
| | | | | Race (nonwhite) | 0.071 | ns | 0.018 | ns | 0.144 | le 0.05 | -0.017 | ns
| | | | | Prior offending | 0.486 | le 0.01 | 0.656 | le 0.01 | 0.414 | le 0.01 | 0.613 | le 0.01
Record# | Study Quality | | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | Risk Factors Studied | | Implications
| Sample Size | | Inclusion/Exclusion Criteria
395 | [underlined: Study Design]: Prospective Cohort Study (Rand's California and Oregon Study - 6 year followup study) | | [underlined: Study Period (begin, end):] Used data collected in 1990 | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Saner 1996 J Adoles Health | [underlined: Study Quality Score:] Poor (retention <80%) | | [underlined: Place (city, state):] California and Oregon | [underlined: Outcome measure] | To examine the risk and protective factors for different types of violent behavior in a sample of high school age adolescents drawn from the general population.
| [underlined: Sample size]: 4,586 (70% of the baseline sample) | | [underlined: Study Setting:] Junior high and middle schools | Violent behavior in the past year: Any violence, persistent hitting, and predatory violence | [underlined: Odds Ratio from Logistic Regression for] Persistent Hitting
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | | [underlined: Study Population:] High school seniors and high school dropouts. | [underlined: Definition] | Risk Factor | Total | Male | Female
| Age: Not specified | | [underlined: Inclusion/Exclusion Criteria]: Not specified | Any violence is equal to one if any (or all) of these violent behavior: 1) gang fights, | Demographic
| Risk factors measured from 7 - 12 grades; | | [underlined: Main independent factor(s):] | 2) use of force or strong arm methods to things from people, | Male gender | 1.6*
| Outcome measured at 12 grades. | | Demographic risk factors: | 3) carry a hidden weapon | Disrupted family | 1.0 | 0.8 | 1.4*
| Gender: | | • Gender | 4) attack someone with the idea of seriously to hurt or kill, | Negative life events
| 2476 (54%) female | | • Disrupted family status | 5) hit or threaten to hit someone in family, and | Recent separation/divorce | 1.0 | 1.0 | 1.0
| 2110 (46%) male | | • Limited income | 6) hit or threaten to hit someone not in your family. | Death of parent | 1.2 | 1.6 | 0.9
| Race: | 71% white | • Low socioeconomic status | Persistent hitting is defined as hitting family members or acquaintances three or more times in the past year. | Lost job | 1.3* | 1.2 | 1.5*
| | 8% African- American | • Parent's educational level | Predatory violence is defined as involvement in gang fights, the use of strong arm methods, carrying a hidden weapon, and attacking with intent to hurt or kill. | Behavioral risk factors
| | 9% Hispanic | • High mobility | [underlined: Type] | Nonviolent felony | 1.9* | 1.8* | 2.3*
| | 9% Asian the rest as multiethnic or Indian | Negative life events to parent(s) in past 2 years: | Gang fight, other serious injury or harm | Minor delinquency | 2.3* | 2.3* | 2.4*
| | | • Separated/divorced | [underlined: Circumstance/Situational Context, Proactive/Reactive; Weapon used; Victim-offender relationship:] Not specified | Drug selling | 2.2* | 2.1* | 2.8*
| | | • Death | [underlined: Adverse Health Outcome]: Not specified | Problem drug use | 1.1 | 1.3* | 0.9
| | | • Lost job 2 or more months | [underlined: Are mechanisms of violence theorized?] | Early drug use | 1.1* | 1.2* | 1.1
| | | Behavior risk factors: | No | Full time work | 1.3* | 1.6* | 1.0
| | | • Involvement with drugs | | Environmental
| | | • Dropping out of school | | Drug use by friends | 1.2 | 1.1 | 1.4*
| | | • Nonviolent felony offenses | | Drug use by parents | 1.3* | 1.3 | 1.4*
| | | • Minor delinquency | | Low academic orientation | 1.3* | 1.2 | 1.5*
| | | Environmental risk factors or institutional bonds: | | Low religiosity | 1.0 | 1.3 | 0.7*
| | | • High perceived drug use by parents or friends | | Low parental support | 1.6* | 1.3* | 2.1*
| | | • Negative academic orientation | | Low peer support | 0.9 | 0.8 | 1.0
| | | • Low religiosity | | *significant at p<0.05
| | | • Low parental affection | | [Only the findings for Persistent Hitting are reported here. Other violence indicators included non-violent behaviors].
| | | • Little sense of peer connectedness
| | | [underlined: Instruments]: Investigator-developed
Record # | Study Quality | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | Risk Factors Studied | | Implications
| Sample Size | Inclusion/Exclusion Criteria
7870 | [underlined: Study Design]: Prospective Cohort Study (part of study of family stress and coping in Iowa) | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] Dating violence in waves 4 and 5 | [underlined: Violence Outcome]
Simons 1998 J Marriage and the Family | [underlined: Study Quality Score:] Poor (attrition rate>20%) | Baseline: Spring 1989 | [underlined: Definition] | The objective of this study was to assess the influence of corporal punishment and witnessing parental marital violence, and the protective effects of involved supportive parenting, on the development of delinquent or antisocial behaviors and dating violence of adolescent boys.
| [underlined: Sample size]: | Follow-up: yearly for 5 years | “When you have a disagreement with your girlfriend, how often do you hit, push, grab or shove her.” | [underlined: Correlation with Dating Violence (n=113)]
| Boys & parents: | [underlined: Place (city, state):] 8 counties in North Central Iowa | [underlined: Instrument used to measure outcome] | | R | p
| Wave 1: 205 | [underlined: Study Setting:] Private and public schools | Conflict Tactics Scale | Involved/Supportive Parenting | -0.06 | ns
| All 5 waves: 163 (79.5%) | [underlined: Study Population:] 7^th^ grade boys with 2-parent families from private and public schools who have been dating. | [underlined: Type:] Dating violence | Corporal Punishment | 0.12 | ns
| Analysis: 113 of 163 who have been dating | [underlined: Inclusion criteria:] See above | [underlined: Circumstance/Situational Context; Proactive/Reactive Weapon used:] not specified | Marital violence | -0.01 | ns
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | [underlined: Exclusion criteria:] Not dating | [underlined: Victim-offender relationship] | Delinquent behavior | 0.28 | <=0.05
| Age: Seventh grade boys followed annually for five years | [underlined: Main independent factor(s):] | Girlfriend-boyfriend | [underlined: Results of Structural Equation Modeling (γ)]
| Gender All male | Measured in waves 1, 2, and 3 | [underlined: Adverse Health Outcome]: Not studied. | Involved/supportive parenting→Delinquent behavior: -0.19
| Race: white | • Use of Corporal punishment | [underlined: Are mechanisms of violence theorized?] | Delinquent behavior→Dating violence: 0.28 (p<=0.05)
| | • Marital violence | Yes | Corporal punishment→Dating violence: 0.20 (p<=0.05)
| | • Involved supportive parenting | There is a discussion of competing theories regarding dating violence: | Although frequent exposure to corporal punishment increased the risk of dating violence, this was not the case for interparental aggression, which did not predict dating violence. Low support and involvement by parents was associated with adolescent delinquency and drug use, which, in turn, predicted involvement in dating violence. Neither family income nor parents' level of education was related to delinquent behavior or dating violence.
| | • Delinquent behavior of youth | 1) Imitation
| | • Dating violence | 2) Broader modeling
| | [underlined: Instrument used to measure factors:] | 3) Social Learning Theory is used to explain 1 or 2.
| | • Conflict Tactics Scale | 4) Dating violence as an expression of a more general antisocial pattern of behavior and orientation arising from ineffective parenting practices.
| | • Delinquency inventory adapted from National Youth Survey
| | • Questions standardized for mothers and fathers
| | [underlined: Covariates]
| | • Reside in small towns or farms
| | • SES
| | • Parental educational level
| | • Parental age
Record # | Study Quality | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | Risk Factors Studied | | Implications
| Sample Size | Inclusion/Exclusion Criteria
4495 | [underlined: Study Design]: Prospective Cohort Study (Pittsburgh Youth Study). | [underlined: Study Period (begin, end):] Not specified | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Stouthamer-Loeber 2001 Development and Psycho-pathology | [underlined: Study Quality Score:] | [underlined: Place (city, state):] Allegheny County, Pittsburgh, PA | [underlined: Outcome measure] | This study addressed whether substantiated maltreatment, and its timing, was related to disruptive behaviors and delinquency in the triple pathways. One of the 3 pathways is the Overt pathway which goes from minor aggression to physical fighting to violence. We report here the findings related to the Overt pathway.
| Element score: | [underlined: Study Setting:] A community setting | Overt pathway: | Overt Pathway | Mal-treated(%) | Control (%) | Odds Ratio (CI)
| Domain score: | [underlined: Study Population:] Two groups of 7^th^ grade male students: Non-risk group - boys with no such behavior. | • Physical fighting (physical fighting, gang fighting) | Aggression | 67.2 | 46.7 | 2.34(1.23–4.44)
| [underlined: Actual sample size]: 500 (250 risky* and 250 non-risky). (Average attrition rate is 7.8%, range from 0 to 12.5%) | [underlined: Inclusion/exclusion criteria:] see above | • Violence (rape, attack, strongarm) | Fighting | 77.0 | 42.6 | 4.52(2.25–9.09)
| [Number of cases who were maltreated and number of controls were not specified. 2 controls were matched for each victim]. | [underlined: Main independent factor(s):] Severity of maltreatment from birth or enrollment to age 18 (based on the Maltreatment Classification System by Cicchetti et al.). | • Age of onset of disruptive and delinquent behavior | Violence | 50.8 | 34.4 | 1.97(1.05–3.68)
| *Risk group consisted of boys who had already demonstrated some disruptive behavior (at least three antisocial or delinquent behaviors | Each type is rated on a 5-point scale: | [underlined: Definition: see above] | Any overt pathway step | 91.8 | 70.5 | 4.69(1.74–12.66)
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | • physical abuse | [underlined: Sources:] Juvenile court records | Number of cases or controls not given.
| Overall: | • sexual abuse | [underlined: Instruments]
| Age(M): 13.8 at first follow-up | • failure to provide-physical neglect | • Child Behavior Checklist (Achenbach)
| Gender: 100% male | • lack of supervision physical neglect | • Diagnostic Schedule for Children
| African-American: 57.5% | • emotional maltreatment | • Self-Reported Delinquency interview
| White: 42.5% | • moral-legal maltreatment | • Youth Self-Report (Achenbach)
| | • educational maltreatment | [underlined: Type]
| | • incorrigibility | Physical fighting, violence
| | [underlined: Sources:] | [underlined: Circumstance/Situational Context; Proactive/Reactive; Weapon used; Victim-offender relationship;] Not specified
| | • Children and Youth Services records | [underlined: Adverse Health Outcome]: Not studied
| | | [underlined: Are mechanisms of violence theorized?]
| | | Yes - The dsiiruptive-delinquent pathways. The steps in the "authority conflict pathway applies to boys up to age 12 years, because after that age truancy becomes more common. Because most maltreatment happens in the home, one could expect that conflict with authority figures is likely to happen. Another hypothesis is that the threat of maltreatment reduces authority conflict.
Record # | Study Quality | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | Risk Factors Studied | | Implications
| Sample Size | Inclusion/Exclusion Criteria
8011 | [underlined: Study Design]: Prospective Cohort Study (8 waves of assessments from the oldest sample of the Pittsburgh Youth Study) | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] | Postulate that parents' recognition of boys' behavior problems often is a first step towards curtailing a delinquent career. The second step is for parents to engage professional help for their child. This paper focuses on parents' recognition of early behavior problems in those boys who eventually become persistent serious delinquent and second whether these youth received professional help.
Stouthamer-Loeber 2002 Criminal Behavior and Mental Health | [underlined: Study Quality Score:] Good | Not stated here. | 4 outcome groups based on presence of outcome in at least 2 assessments over 5 years: | 1. Prevalence of Outcome Groups in Sample
| [underlined: Sample size]: | [The Pittsburgh Youth Study began in 1987] | 1. persistent serious violent offender (PVO) | | Total | ND | PNO | PPO | PVO
| Original: 506 | [underlined: Place (city, state):] Pittsburgh | 2. Persistent serious property offender (PPO) | Percent | 100% | 40.4 | 19.9 | 18.2 | 21.4
| Analysis: 470 (93%) | [underlined: Study Setting:] Public schools | 3. Persistent non-serious offender (PNO) | Estimated n | 470 | 190 | 94 | 86 | 100
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | [underlined: Study Population:] Random sample of 7^th^ grade boys enrolled in the City of Pittsburgh public schools in 1987-1988 | 4. Non-delinquent group (ND) | 2. % with Disruptive behavior Diagnosis at age 13.5
| [underlined: Age] 13 years at beginning of study followed to age 18 | [underlined: Inclusion criteria]: See above | [underlined: Definition] | | | ND | PNO | PPO | PVO
| [underlined: Gender]: males | [underlined: Exclusion criteria:] Not specified | Serious violent crimes include attack to seriously hurt or kill, strong-arm, gang-fight, and rape. | Estimated from Fig 3
| [underlined: Race:] not specified in this article. | [underlined: Main independent factor(s):] | [underlined: Instrument used to measure outcome] | Percent | | 10.1 | 19.0 | 21.0 | 27.7
| From #4834: African-american 47.5% | 3 types of disruptive behavior: | • Self Reported Delinquency Questionnaire | Number | | 19 | 18 | 18 | 28
| Remainder described as “almost all white.” | • ADD - attention deficit/hyperactivity disorder | • Archenbach Youth Self-Report | Chi square for ND vs. PVO: 14.87 (P<.001)
| | • ODD - oppositional defiant disorder | • Child Behavior Checklist | Chi square for ND vs PPO: 6.04 (P<.01)
| | • CD - conduct disorder | [underlined: Type]: see above | [underlined: Chi square for ND vs PNO: 4.13 (p<.05)]
| | [underlined: Instrument used to measure factors:] Diagnostic Interview Schedule for Children (Costello, 1986) | [underlined: Circumstance/Situational Context]
| | [underlined: Covariates] | [underlined: Proactive/Reactive]
| | none | [underlined: Weapon used]
| | | [underlined: Victim-offender relationship]
| | | Not specified
| | | [underlined: Adverse Health Outcome]: Not studied
| | | [underlined: Are mechanisms of violence theorized?]
| | | No
Record # | Study Quality | | Study Characteristic | Outcome (violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | Risk Factors Studied | | Implications
| Sample Size | | Inclusion/Exclusion Criteria
4815 | [underlined: Study Design:] Prospective Cohort Study (Waves 1 and 2 of the Buffalo Longitudinal Study of Young Men (BLSYM) | | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
Welte 1998 J Substance Abuse | [underlined: Study Quality Score:] Good if retention rate only is considered; Poor if participation and retention rates are considered. | | Wave 1- October 1992-January 1994 | [underlined: Outcome measure] | ANCOVA: dependent variable: violent offending wave 2(N=568)
| [underlined: Sample size] | | Wave 2– 18 months later | Violent Offending (constructed from the National Youth Survey (Elliott et al., 1985) | | df | F | P
| Wave 1: 625 (448 delinquent; 117 non-delinquent) | | [underlined: Place (city, state):] Buffalo, NY | [underlined: Definition] | Control/Covariates
| Wave 2: 596 (95%) | | [underlined: Study Setting:] Private interview rooms at the Research Insitute on Addictions | Total # of times in past year committing: robbery, rape, gang fights, simple and aggravated assault. | Race | 1 | 1.6 | 0.200
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | | [underlined: Study Population:] Males 16–19 with over-sampling of delinquent adolescents (3 or more items answered in the delinquent direction) | [underlined: Type:] See above | Violent Offending wave 1 | 1 | 3.1 | 0.080
| Age range: 16–19 years | | [underlined: Inclusion criteria:] see above | [underlined: Circumstance/Situational Context; Proactive/Reactive; Weapon used; Victim-offender relationship:] Not specified | Alcohol consumption wave 1 | 1 | 31.1 | <0.0001
| Gender 100% male | | [underlined: Exclusion criteria:] | [underlined: Adverse Health Outcome:] Not studies | Linear Trend Terms
| Race | | • Not English speaking | [underlined: Are mechanisms of violence theorized?] | Verbal Intelligence wave 2 | 1 | 3.5 | 0.062
| White | 49% | • Gravely ill | Yes | Trail making wave 2 | 1 | 1.8 | 0.179
| Af. Am | 45% | • Not able to communicate | Heavy drinking and lower intelligence is a dangerous combination. Pernanen (1981) suggests alcohol causes violent behavior by reducing intellectual functioning and promoting misunderstanding. Miczek (1994) suggests Left-hemisphere dysfunction interferes with linguistic processing and may be causal to violence in that poorer communication contributes to the mis-interpretation of events and motives. Moffit and Henry (1989) have a competing theory linked with alcohol reducing inhibitions. Persons under the influence of alcohol and with low intelligence would have weaker self-restraint. | Alcohol consumption wave 2 | 1 | 18.0 | <0.0001
| Other | 6% | [underlined: Main independent factor(s):] | | Interactions
| | | • Alcohol consumption (from quantity and frequency for 6 forms of alcohol) | | Race by alcohol consumption wave 2 | 1 | 11.8 | 0.001
| | | • Verbal intelligence (by Ammons Quick Test) | | Verbal Intelligence wave 2 by alcohol consumption wave 2 | 1 | 17.7 | <0.0001
| | | • Visual-motor intelligence (by Trail Making Test, Forms A and B) | | Trail making wave 2 by alcohol consumption wave 2 | 1 | 5.9 | 0.016
| | | • Race | | Violent crimes in past year wave 2 broken down by alcohol consumption and verbal intelligence, N=596
| | | [underlined: Covariates] | | Alcohol Consumption (ounces per day[underlined: )] | Wave 2 mean violent crimes in past year | Verbal Intelligence (high to low) | Wave 2 mean violent crimes in past year
| | | Violent offending at baseline | | 0.0 | 5 | 1 | 3
| | | | | 0.01–0.1 | 2 | 2 | 3
| | | | | 0.1–0.2 | 2 | 3 | 43
| | | | | 0.2–0.4 | 7 | 4 | 14
| | | | | 0.4–0.8 | 2 | 5 | 5
| | | | | 0.8–1.2 | 20 | 6 | 21
| | | | | 1.2–2.1 | 7 | 7 | 2
| | | | | 2.1–3.9 | 24 | 8 | 8
| | | | | 3.9–20.5 | 96 | 9 | 18
| | | | | | | 10 | 65
| | | | | Overall | 17 | Overall | 17
| | | | | [underlined: Results:] Alcohol use in wave 1 was strongly predictive of violent offending in wave 2. Race does not predict violent offending. Small and marginally significant main effect of verbal intelligence on violent offending. Heavier drinking men tend to be more violent. Violent offending is far higher among the lowest intelligence decile.
Record # | Study Quality | | Study Characteristic | Outcome (Violence) Definition and characterization. | Findings
Author Year, Jnl | Group(s) Demographics | | Risk Factors Studied | | Implications
| Sample Size | | Inclusion/Exclusion Criteria
9447 | [underlined: Study Design]: Prospective cohort study (Pittsburgh Youth Study - 4 year follow-up of 3 school-grade cohorts (grades 1, 4 and 7) (6–12 years) | | [underlined: Study Period:] 1987-1992 | [underlined: Outcome (violence):] Serious violence during the study period. | [underlined: Violence Outcome]
Zhang 1997 J Quantitat Criminol | [underlined: Study Quality Score:] | | [underlined: Place (city, state):] Pittsburgh, PA | [underlined: Definition] | To examine developmental trends in delinquent attitudes and behaviors for the Oldest sample (Grade 7 at study start) (n≈500)
| Unsure | | [underlined: Study Setting:] Public schools | • Severely attacking or hurting people with a weapon, strong-arming | [underlined: Odds Ratios (p-values) for Pairwise Attitude-Behavior relations]
| Attrition rate not specified | | [underlined: Study Population:] Sample of males from grades 1, 4, and 7 from Pittsburgh public school system. Each grade consisted 250 high risk of disruptive behavior and 250 not. | • Severely attacking or hurting people with a weapon, strong-arming, gang fighting, killing | Oldest sample (grade 7 at study start):
| [underlined: Sample size]: 1517 for 3 cohorts; about 500 per cohort (only the results for the oldest cohort used). | | [underlined: Inclusion criteria:] See above | [underlined: Instrument used to measure outcome] | | Serious violence offenses
| [underlined: Age] | | [underlined: Exclusion criteria:] None specified | Items selected from National Youth Survey instrument. | | Yr 1 | Yr 2 | Yr 3 | Yr 4
| Mean Not specified | | [underlined: Main independent factor(s):] | [underlined: Type:] see definition | Attitude to serious violence
| Grades 1, 4, and 7 (only results from grades 4 and 7 sample will be reported) | | • Attitude toward delinquent behavior | [underlined: Circumstance/Situational Context; roactive/Reactive; Weapon used; Victim-offender relationship] | Yr 1 | 3.9*** | 3.1**
| Range 6–12 | | • delinquent behavior | Not specified | Yr 2 | | 3.7*** | 4.6**
| [underlined: Gender] 1517 (100%) male | | [underlined: Instrument used to measure factors:] | [underlined: Adverse Health Outcome]: Not studied | Yr 3 | | | 9.5*** | 4.6***
| [underlined: Race] | | • Attitude measures: PI developed | [underlined: Are mechanisms of violence theorized?] | Yr 4 | | | | 5.1***
| African-Amer | 58% | • Behavior measures: SRD (National Youth Survey) | Yes | ** p<.01; ***p<.001
| Caucasian | 41% | [underlined: Covariates] | Delinquent attitudes and behaviors were related to each other in various patterns, and age was a defining factor that provided much of the explanation for the inconsistencies in research findings. | [underlined: Growth curve estimates (p-values) as function of Age polynomial]
| Other | 1% | Age | | | Serious violence attitudes | | Serious violence behaviors
| | | | | Age | 0.0044 (<0.01) | | 0.0169 (<0.01)
| | | | | Age^2^ | 0.0006 (ns) | | 0.0021 (ns)
| | | | | Age^3^ | 0.0002 (ns) | | 0.0002 (ns)
| | | | | [underlined: Change (p-value) between adjacent ages in Violent attitudes and behaviors by Random Regression Models]
| | | | | Ages | Serious violence attitudes | | Serious violence behaviors
| | | | | 9–10 | 0.0008 (ns) | | -0.0678 (ns)
| | | | | 10–11 | 0.0010 (ns) | | -0.0002 (ns)
| | | | | 11–12 | 0.0172(<0.01) | | 0.0069 (ns)
| | | | | 12–13 | -0.0045 (ns) | | -0.0014 (ns)
| | | | | 13–14 | -0.0009 (ns) | | 0.0311 (ns)
| | | | | 14–15 | 0.0103 (ns) | | 0.0552 (<0.01)
| | | | | 15–16 | 0.0164 (<0.01) | | -0.0194 (ns)
| | | | | 16–17 | -0.0038 (ns) | | 0.0371 (ns)
| | | | | 17–18 | 0.0372 (ns) | | 0.1023 (ns)

## Appendix C2

Evidence Table 02. Effectiveness of Prevention Interventions to Violent Behavior and Adverse Health Outcome

Record# | Study Quality | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
1729 | [underlined: Study Design]: A pretest-posttest control group design, with random assignment to conditions and 4-year follow-up for arrests. | [underlined: Time (begin, end):] Not specified | [underlined: Description of Program] | [underlined: Primary Objective]
Borduin 1995 J Consulting and Clinical Psych | [underlined: Individual study quality score] | [underlined: Place (city, state):] Missouri | Multisystemic Therapy (Henggeler & Borduin, 1990) - | To examine the long term effects of MST vs IT on the prevention of criminal behavior and violent offending among juvenile offenders at high risk for committing additional serious crimes.
| Poor (Comparability of groups was maintained; attrition>20%.) | [underlined: Study Population] | • present-focused and action-oriented | [underlined: Outcome 1: RBPC score (mean±SD)]
| [underlined: Sample size (initial and actual)]: | Juvenile offenders at high risk for committing additional serious crimes | • directly addresses intrapersonal and systemic factors known to be associated with adolescent antisocial behavior. | | [underlined: Treated (n=70)] | [underlined: Control (n=56)]
| Overall= 176 families (140, 79.5%, completed treatment). | [underlined: Inclusion criteria]: | • individualized and highly flexible | Pre | 0.17±0.74 | -0.15±0.80
| Intervention Group (Grp 1)- Multisystemic therapy(MST) =92 (77, 84%, completed treatment) | Consecutive referrals by juvenile court personnel included all families in which the youth: | [underlined: Name of program] | Post | -0.54±0.81 | 0.64±0.85
| Control Group (Grp 2)- Individual therapy (IT)=84 (63, 75%, completed treatment) | • Were ages 12 – 17 | MST (Part of Missouri Delinquency Project) | | Significant decrease | Significant increase
| [underlined: Age, gender & race groups]: | • Had at least 2 arrests | [underlined: Level] Tertiary | [underlined: Outcome 2: 4-year Arrest Rate]
| Age 14.8 (SD 1.5) | • Currently lived with at least one parent figure | [underlined: Kind of program] | | [underlined: Treated (n=92)] | [underlined: Control (n=84)]
| Gender – 67.5% male | [underlined: Exclusion criteria]: | Multisystemic approach with youth and their families designed to empower parents with the skills and resources to independently address future problems. | % arrested | 26.1 | 71.4
| Race – 70% white, | • signs of psychosis or dementia | [underlined: Mechanism of delivery] | A log-rank test comparing the survival function (probability of not being arrested) revealed significant difference χ2 (1, N=176)=46.4, p<.0001.
| 30% African American | [underlined: Moderating/mediating factors] | Individual and family intervention | [underlined: Outcome 3:]
| Age, gender, and race only provided for all participants and not for specific intervention groups. | • gender, ethnic background, number of arrests for violent crime before treatment | [underlined: Target population] | [underlined: (a) Number of Serious Crimes (mean±SD)]
| | [underlined: Outcome 1: violence] | Adolescent offenders | Completers and dropouts
| | [underlined: Measure]s: | [underlined: Setting where intervention took place] | [underlined: Treated (n=92)] | [underlined: Control (n=84)] | [underlined: F (p)]
| | 1. 4-year change in adolescent behavior problems as measured by mothers' reports on the 89-item Revised Behavior Problem Checklist (RBPC). | Sessions were generally held in the families home and in community locations (school, rec center, etc.) | 1.71±1.04 | 5.43±3.62 | 10.4(<.002)
| | 2. 4-year change in arrest rate of adolescent criminal activity | [underlined: Setting where subjects were recruited] | Completers Only
| | 3. 4-year change in seriousness of adolescent criminal activity. | Identified in Juvenile court and contacted by phone or home visit. | [underlined: Treated (n=77)] | [underlined: Control (n=63)] | [underlined: F (p)]
| | 4. 4-year change in arrests for violent crimes. | [underlined: Person delivering program] | 1.57±0.85 | 4.41±3.89 | 10.4(<.002)
| | [underlined: How measured:] Criminal arrests and severity measured by record review of juvenile court, local police and department of Public Safety records from the time of the adolescent's release from juvenile court supervision. | Graduate students in clinical psychology | (b) Seriousness of Crime [underlined: (mean±SD)]
| | The seriousness of arrest was measured in a 17 point scale (1=truancy, 4=disorderly conduct, 8=assault/battery, 11=grand larceny, 13=unarmed robbery , 17=murder). | [underlined: Time period/duration/frequency] | Completers and dropouts
| | Circumstance: not specified | MST families completed a mean of 23.9 hours of treatment (SD =8.2, range 5–49), IT families completed a mean of 28.6 hours (SD=9.8, range 15 –72). These means were significantly different (p<.01) | [underlined: Treated (n=92)] | [underlined: Control (n=84)] | [underlined: F (p)]
| | Proactive/reactive: not specified | | 5.17±5.01 | 9.40±3.37 | 20.1(<.001)
| | Weapon used: Not specified | | Completers Only
| | Victim-offender relationship: not specified | | [underlined: Treated (n=77)] | [underlined: Control (n=63)] | [underlined: F (p)]
| | [underlined: Outcome 2: Adverse health] | | 6.35±4.67 | 9.67±3.38 | 12.8(<.001)
| | Not addressed | | [underlined: Outcome 4: Arrests for Violent Crimes]
| | [underlined: Outcome 3: Effectiveness] | | Completers and dropouts
| | Change in outcomes | | F(2, 173)=11.7, p<.0008
| | [underlined: Outcome 4: Safety] | | Completers Only
| | Not studied | | F(2, 137)=8.66, p<.003.
| | | | [No other statistics were reported.]
| | | | Generalization of Effectiveness: MST completers and drop outs were less likely to be arrested for violent crimes following treatment than were youth who participated in the IT group (even after controlling for the number of arrests for violent crime before treatment)
| | | | MST was found to be equally effective with youths of different gender and ethnic backgrounds.
Record# | Study Quality | | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | | Inclusion/Exclusion Criteria
| | | Outcome Definition
5246 | [underlined: Study Design]: Randomized control trial. Each grade has 3 teams of 100 to 140 students. 2 teams in each grade randomly to the intervention and 1 team to the control. | | [underlined: Time (begin, end):] January to April 1995 | [underlined: Description of Program] | To evaluate the impact of SMART Talk on aggressive behaviors.
Bosworth 2000 Am J Health Behav | [underlined: Individual study quality score] | | [underlined: Place (city, state):] A major midwestern metropolis | This computer-based multimedia program was designed to teach adolescents how to resolve interpersonal issues without violence. | Mean (SD) of aggression score
| • no intent-to-treat analysis | | [underlined: Study Population:] 6th, 7th and 8th grades students | [underlined: Name of program] | (A) Both Gender, grade was covariate
| • groups not comparable at the outset. | | [underlined: Inclusion criteria]: Not specified | SMART Talk (Students Management Anger and Resolution Together) | Time | Intervention | Control
| [underlined: Sample size (initial and actual)]: | | [underlined: Exclusion criteria]: Not specified | [underlined: Level:] Primary | | (n=321) | (n=195)
| Overall: 558 completed initial survey; 538 completed follow-up survey. After exclusions, actual in analysis was 516. | | [underlined: Moderating/mediating factors] | [underlined: Kind of program] | Pre | 14.98 (5.64) | 15.06 (5.91)
| 1) Intervention group: N=321 | | Grade was the covariate in the multivariate analysis. | Anger management, perspective taking, dispute resolution | Post | 14.98 (5.80) | 15.27 (6.17)
| 2) Control group: N=195 | | [underlined: Outcome 1: violence] | [underlined: Mechanism of delivery] | (B) Males, grade was covariate
| [underlined: Age]: | 42% (232) 6^th^ graders, | [underlined: Measure]: Self-reported aggressive behavior measured with 4 items from the U of Texas Hlth Science Center Aggression Scale and 3 items from the Conflict Tactic Scale in the past 30 days. | Computer-based multimedia program | Time | Intervention | Control
| | 31% (173) 7^th^ graders, | [underlined: Definition]: “hit back when hit first”, “pushed, slapped, shoved, or kicked other students”, “got into a physical fight when angry”, and "threatened to hurt or to hit another student. Scores ranged from 7 to 28. | [underlined: Target population] | | (n=145) | (n=90)
| | 27% (153) 8^th^ graders | [underlined: Outcome 2: Adverse health] | 6th - 8th grade students | Pre | 15.88 (5.92) | 16.64 (6.32)
| [underlined: Gender]: | 46% (258) males, | Not specified | [underlined: Setting where intervention took place] | Post | 16.14 (6.23) | 16.89 (6.46)
| | 54% (300) females | [underlined: Outcome 3: Effectiveness] | School | (C) Females, grade was covariate
| [underlined: Race]: | | Not specified | [underlined: Setting where subjects were recruited] | Time | Intervention | Control
| 84% (468) | Caucasian | [underlined: Outcome 4: Safety] | School | | (n=176) | (n=105)
| 9% ( 52) | African-American | Not specified | [underlined: Person delivering program] | Pre | 14.24 (5.32) | 13.71 (5.18)
| 4% ( 19) | Biracial | | Self access to the software | Post | 14.03 (5.25) | 13.87 (5.58)
| 4% ( 19) | Other | | [underlined: Time period/duration/frequency] | (D) 6th Graders
| 1) Intervention group | | | Access to program was provided during the entire semester. Students had free access and during some class times. | Time | Intervention | Control
| Age: 42% 6^th^ graders | | | | | (n=108) | (n=106)
| Gender: 45% males | | | | Pre | 15.94 (5.57) | 14.26 (5.40)
| Race: Not specified | | | | Post | 15.68 (5.93) | 15.33 (6.08)
| 2) Control group | | | | (E) 7th Graders
| Age: 25% 6^th^ graders | | | | Time | Intervention | Control
| Gender: 46% males | | | | | (n=114) | (n=42)
| Race: Not specified | | | | Pre | 14.61 (5.52) | 17.56 (6.51)
| | | | | Post | 14.66 (5.49) | 16.24 (6.34)
| | | | | (F) 8th Graders
| | | | | Time | Intervention | Control
| | | | | | (n=99) | (n=47)
| | | | | Pre | 14.36 (5.78) | 14.64 (5.96)
| | | | | Post | 14.61 (5.99) | 14.26 (5.94)
| | | | | No significant reduction in aggression in either group for gender or grade subgroups.
Record # | Study Quality | | | | | | | Time/Place | Prevention intervention: Definition and characteritic | Findings
Author Year, Jnl | Group(s) and Sample Size | | | | | | | Inclusion/Exclusion Criteria
| | | | | | | | Outcome Definition
5301 | [underlined: Study Design] Nonrandomized controlled study with pre and post intervention comparison. Six study groups, 3 accepted treatment, 3 declined treatment | | | | | | | [underlined: Time (begin, end):] Entire 1997-1998 school year and first semester of the 1998-1999 school year. | [underlined: Description of Program] | [underlined: Goa]l: To evaluate the impact of a conflict resolution skills training program that is offered as an alternative to out-of-school suspension in reducing acts of physical violence among high school students.
Breunlin 2002 J Educational Research | [underlined: Individual study quality score] | | | | | | | [underlined: Place (city, state):] Western suburbs of Chicago, I1. | The core premises and skills of conflict resolution are derived from the principles and practices of mediation. The structure and format of this program is predicated on substantial evidence that violence is largely learned and consequently can be prevented through teaching alternatives to violence. | [underlined: Number re-suspended for fighting and physical violence index (PVI)]
| Poor (potential confounders not controlled for) | | | | | | | [underlined: Study Population] Public High School Students that were suspended between 8/97 and 12/98 | [underlined: Name of program] | | #/Total in group (%) | PVI
| [underlined: Sample size (initial and actual):] | | | | | | | [underlined: Inclusion criteria] Suspended during time frame | Alternative for Suspension for Violent Behavior (ASVB) | All groups | 16/165(10%) | 0.20
| Total=165 | | | | | | | [underlined: Exclusion criteria] Not noted | [underlined: Level:] Secondary | Group 1 (Tx) | 1/ 25(4%) | 0.06
| All | Gp1 | Gp2 | Gp3 | Gp4 | Gp5 | Gp6 | [underlined: Moderating/mediating factors:] | [underlined: Kind of program] | Group 2 (Con) | 5/ 41 (12%) | 0.18
| 165 | 25 | 41 | 7 | 36 | 10 | 46 | type of suspension and enrollment in program | • Teaching social problem-solving and thinking skills | Group 3 (Tx) | 1/ 7 (14%) | 0.41
| Grade | | 12th | 11th | 10th | | 9th | Gp 1: fighting-in ASVB | • Family intervention | Group 4 (Con) | 2/ 36 ( 6%) | 0.11
| All | | 4% | 11% | 30% | | 54% | Gp 2: fighting-declined ASVB | • Anger management | Group 5 (Tx) | 1/ 10 (10%) | 0.27
| Gp1 | | 12% | 8% | 39% | | 44% | Gp 3: oth violence-in ASVB | [underlined: Mechanism of delivery] | Group 6 (Con) | 6/ 46 (13%) | 0.32
| Gp2 | | 5% | 7% | 27% | | 61% | Gp 4: oth violence-declined ASVB | Each family meets with a Trainer for 6 hours | Treatment | 3/ 42 ( 7%) | 0.17
| Gp3 | | 14% | 29% | 57% | | 0% | Gp 5: non-violence-in ASVB | [underlined: Target population] | No Treatment | 13/123 (11%) | 0.21
| Gp4 | | 3% | 19% | 28% | | 50% | Gp 6: non-violence-declined ASVB | High School Students who have been suspended | • Statistically significant differences between groups were not observed but important trends in data were identified.
| Gp5 | | 0% | 30% | 50% | | 20% | [underlined: Outcome 1: physical violence] | [underlined: Setting where intervention took place] | • Analyses of Pooled treatment and non treatment groups indicated a trend of treatment groups faring better on the three out of school suspension indices.
| Gp6 | | 0% | 2% | 24% | | 74% | [underlined: Measure]: rate of resuspension for acts of physical violence per year, measured by the Physical Violence Index (PVI) | Family Institute satellite office near school site | • Lack of random assignment to treatment and non-treatment groups opens the possibility that differences in the acceptors and refusers explain the results instead of the particular intervention.
| [underlined: Gender: % Male] | | | | | | | [underlined: Definition] - physical confrontation | [underlined: Setting where subjects were recruited]
| All | Gp1 | Gp2 | Gp3 | Gp4 | Gp5 | Gp6 | [underlined: Type]- physical violence | High School
| 82 | 68 | 83 | 100 | 89 | 80 | 83 | [underlined: Circumstance, Proactive/reactive, Weapon used, Victim-offender relationship]; Not reported | [underlined: Person delivering program]
| Race | | Af/Am | Hisp | Cauc | API | Other | [underlined: Outcome 2: Adverse health] | Trainer- qualifications not described
| All | | 10% | 12% | 74% | 2% | 2% | Not reported | [underlined: Time period/duration/frequency]
| Gp1 | | 16% | 20% | 60% | 0% | 0% | [underlined: Outcome 3: Effectiveness] | 6 hours spread over 4–90 minute sessions
| Gp2 | | 22% | 12% | 61% | 0% | 5% | Reduced rate of resuspension.
| Gp3 | | 14% | 0% | 71% | 0% | 14% | [underlined: Outcome 4: Safety]
| Gp4 | | 3% | 8% | 83% | 6% | 0% | Not reported
| Gp5 | | 0% | 0% | 100% | 0% | 0%
| Gp6 | | 2% | 15% | 80% | 2% | 0%
Record # | Study Quality | | | | Time/Place | Prevention Intervention:Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | | | | Inclusion/Exclusion Criteria
| | | | | Outcome Definition
1308 | [underlined: Study Design]: Nonrandomized control trial | | | | [underlined: Time (begin, end):] August 1994-March 1995 | [underlined: Description of Program] | Low concentrations of serotonin in the CNS have been associated with increased aggression in humans. Studies with adults shows that SSRIs reduce aggressive behavior in depressed adults. This study attempts to replicate this with adolescents.
Constantino 1997 J Child & Adolesc Psycho-pharma-cology | [underlined: Individual study quality score] | | | | [underlined: Place (city, state):] St. Louis, Missouri | Intervention group received at least 5 week treatment with SSRI, may use fluoxetine, paroxetine or sertraline. May have concurrant use of other psychotropic medication. Control group received no SSRI treatment. | Comparison of Aggressive events/week for 13 adolescents while treated with SSRI's and While not treated with SSRI's, shown only for those adolescents who were observed both on and off SSRIs during hospitalization
| Poor (key confounders were given little or no attention). | | | | [underlined: Study Population]: Psychiatrically hospitalized adolescent (not selected for aggressiveness) | [underlined: Name of program] | | [underlined: # of physically aggressive events towards other per week]
| [underlined: Sample size (initial and actual)]: | | | | [underlined: Inclusion criteria]: | Selective serotonin reuptake inhibitors (SSRIs) treatment | | Mean | SD | Paired-t | p
| Total - initial: | 63 | | | • Hospitalized for at least 4 weeks from 8/94 – 3/95 | [underlined: Level]: secondary | Off SSRIs | 0.50 | 0.88 | -1.33 | 0.21
| Total - actual | 58 | | | • Received trial of SSRI's for at least 5 weeks, initiated and completed in hospitalization | [underlined: Kind of program:] medication | On SSRIs | 0.69 | 1.09
| Treatment Group (Grp 1): | 19 | | | [underlined: Exclusion criteria]: | [underlined: Mechanism of delivery] | | [underlined: # of physically aggressive events towards others per week]
| Control Group (Grp 2) | 39 | | | • Primary diagnoses drug or alcohol dependence | Daily treatment with SSRI. | | | N | Mean | SD
| [underlined: Age, gender & race groups]: | | | | • Received SSRI for less than 5 weeks | [underlined: Target population] | SSRI treated patients
| | All | Grp1 | Grp2 | [underlined: Moderating/mediating factors] | Youth in psychiatric hospital | While Treated with SSRIs
| Age | 13–17 | | | Discharge Diagnosis (e.g. disruptive, affective or psychotic); Age; gender | [underlined: Setting where intervention took place] | Disruptive | | 8 | 0.49 | 0.38
| Gender | Treated group | | | [underlined: Outcome 1: violence] | Psychiatric Hospital | Affective | | 9 | 0.18 | 0.39
| | 11 M | | | [underlined: Measure]: Summation of behavior over 1 week based on a modified Overt Aggression Scale | [underlined: Setting where subjects were recruited] | Psychotic | | 2 | 2.21 | 2.54
| | 8 F | | | [underlined: Definition]: “physical aggression toward other people” | Psychiatric hospital | While [underlined: Not] Treated with SSRIs
| Race not specified | | | | [underlined: Type] Aggression towards others | [underlined: Person delivering program] | Disruptive | | 7 | 0.32 | 0.45
| [underlined: Comment:] The Overt Aggression Scale includes Aggression against others as only one component, | | | | [underlined: Circumstance] Observed in hospital setting | Health care providers | Affective | | 5 | 0.23 | 0.43
| | | | | [underlined: Proactive/reactive; Weapon used; Victim-offender relationship]: not specified. | [underlined: Time period/duration/frequency] | Psychotic | | 1 | 3.08 | 0
| | | | | [underlined: Outcome 2: Effectiveness] | At least 5 weeks duration of treatment that were initiated and completed during hospitalization. Starting dose was 15±5mg and dosage was raised at a mean rate of 5 mg every 4 days up to a mean dose of 25±10mg daily. | Contrast Group
| | | | | Reduction in violence | [underlined: Notes if any] | Disruptive | | 19 | 0.64 | 0.71
| | | | | [underlined: Outcome 3: Adverse health] | SSRSI treated patients did not differ significantly in their diagnosis, length of stay, or level or aggression. | Affective | | 15 | 0.19 | 0.41
| | | | | Not studied | | Psychotic | | 5 | 1.49 | 2.33
| | | | | [underlined: Outcome 4: Safety] | | • There was no statistically meaningful improvement in the level of aggressive behavior during the SSRI trials.
| | | | | Adverse effects | | • 2 minor adverse effects of SSRIs. One experienced dose dependent tremor and insomnia and another developed mild recurrent headaches. Neither patient required discontinuation of drugs.
Record # | Study Quality | Time/Place | Prevention Intervention: Definition and Characteritic | Findings
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
393 | [underlined: Study Design] Pre and Post Intervention design for two intervention programs. Two schools were randomly assigned one of the two programs | [underlined: Time (begin, end)] Two 6-week time blocks in November and December 1993 and February and March, 1994. | [underlined: Description of Program] | The purpose of this study was to compare the effectiveness of the two curriculums in reducing use and frequency of violence in middle school students living in or around public housing.
DuRant 1996 J Adoles Health | [underlined: Individual study quality score] | [underlined: Place (city, state):] Augusta, GA | [underlined: Name of program] | [underlined: Violence Prevention]
| Poor (no control program) | [underlined: Study Population:] Students in Middle School (grades 6, 7, and 8) | 1) Violence Prevention Curriculum for Adolescents | | | Pre-test Mean(SD) | Post-test Mean(SD)
| [underlined: Sample size (initial and actual):] | [underlined: Inclusion criteria:] | 2) Conflict Resolution: A Curriculum for Youth Providers | Use of violence | | .82(1.79) | .39(1.28)
| 1) Violence Prevention Curriculum for Adolescents | 1) Violence Prevention: students who were in afternoon elective classes | [underlined: Level:] both are primary | Freq of fighting | | 1.37(1.75) | .51(1.26)
| N=151 (27% sixth, 40% seventh, 33% eighth) | 2) Conflict Resolution: students who had free class periods during the morning | [underlined: Kind of program] | Freq of injury | | .15( .48) | .20(.78)
| 2) Conflict Resolution: A Curriculum for Youth Providers | [underlined: Exclusion criteria] Not specified | 1) Didactic and cognitive, combining information and role-playing. | [underlined: Conflict Resolution]
| N=74 (41% sixth, 27% seventh, 32% eighth) | [underlined: Moderating/mediating factors] | 2) Conflict resolution, skill building exercises, role-playing | | | Pre-test Mean(SD) | Post-test Mean(SD)
| [underlined: Age, gender & race groups: All] | Not specified | [underlined: Mechanism of delivery] | Use of violence | | .73(1.65) | .51(1.38)
| Age: Not specified | [underlined: Outcome 1: violence] | Both are school curriculum | Freq of fighting | | 1.74(1.99) | 1.03(1.51)
| Gender: Male 48.4% (109) | Measure: | [underlined: Target population] | Freq of injury | | .59(1.08) | .28(.63)
| Female 51.6% (116) | •Use of Violence in the previous 30 days - assessed on a 7-item scale; | Both are middle school students | [underlined: Probability Levels]
| Race: Black 88.7% (189) | •frequency in previous 30 days of engaging in a physical fight | [underlined: Setting where intervention took place] | | Bet Group | Within Group | Group X Time
| White 10.3% (22) | [underlined: Definition of violence] (same as CDC Youth Risk Behavior Survey and Denver Youth Delinquency Questionnaire): | Both are in classrooms | Use of violence | .92 | .004 | .35
| Native Amer .9% (2) | •openly carried a weapon, | [underlined: Setting where subjects were recruited] | Freq of fighting | .028 | .001 | .62
| 1) Violence Prevention Curriculum for Adolescents | •had been in a fight, | Both are in schools | Freq of injury | .001 | .105 | .018
| Age: Not specified | •had been injured in a fight and required medical attention, | [underlined: Person delivering program] | •Significant (p<.001) reductions in the violence scale by both groups following both interventions, but the groups did not differ at the posttest.
| Gender: Not specified | •had carried a hidden weapon, | Both are delivered by an experienced African-American mental health counselor | •Significant (P≤.022) Gender X Time interaction effect indicated that at pretest the female students had higher use of violence scale scores than did males, but they had significantly lower scores following the intervention.
| Race: 84% Black | •had attacked someone with a weapon or with the idea of seriously hurting or killing them, | [underlined: Time period/duration/frequency] | •Students in both groups had significant (P≤.001) reductions in the frequency of fighting.
| 2) Conflict Resolution | •had used a weapon to stab something from someone, and | Both programs had 10 50-min sessions . Both were conducted at the same time in each school during two 6-week time blocks in November and December 1993 and February and March 1994. | •No significant Group X Time interaction effect in the frequency of fighting.
| Age: Not specified | •had been involved in a gang fight. | | •A significant (P≤.018) Group X Time interaction effect. Students in the violence prevention group had a slight increase in this scale, whereas students in the conflict resolution group reported a significant drop in more severe fighting behaviors.
| Gender: Not specified | [underlined: Outcome 2: Adverse health] | | •A significant (P≤.018) Gender X Group interaction effect on this scale. Males scored higher on this scale at both pretest and posttest, but males in the conflict resolution group demonstrated the greatest reduction in the frequency of fighting resulting in injury requiring medical treatment.
| Race: 100% Black | Definition of outcome measure(s)
| | Injury during a fight servere enough to require medical treatment
| | [underlined: Outcome 3: Effectiveness]
| | Definition of outcome measure(s)
| | •Use of violence in hypothetical situations,
| | •avoidance of violence
| | •use of violence in the previous 30 days
| | •fighting behaviors in the previous 30 days
| | [underlined: Outcome 4: Safety]
| | Definition of outcome measure(s)
| | Not specified
Record # | Study Quality | | Time/Place | Prevention Intervention: Definition and characteritic | Findings
Author Year, Jnl | Group(s) and Sample Size | | Inclusion/Exclusion Criteria
| | | Outcome Definition
1579 | [underlined: Study Design]: Nonrandomized control trial. Two schools received the intervention and two schools that did not receive the intervention served as controls. | | [underlined: Time (begin, end):] Oct 1994-Feb 1995 | [underlined: Description of Program] | To evaluate a Social Cognitive Theory-based violence prevention curriculum among sixth-grade students.
DuRant 2001 J Adoles Hlth | [underlined: Individual study quality score] | | [underlined: Place (city, state):] Augusta, Georgia | The curriculum was based on Social Cognitive Theory with 13 modules. | [underlined: Outcome 1]
| Poor (key confounders not given adequate attention) | | [underlined: Inclusion criteria]: Students in middle schools | [underlined: Name of program] | Mean (SD) of use of violence in previous 30 days (range of scale: 0–20)
| [underlined: Sample size (initial and actual)]: Overall: initial 704, actual 563 | | Living in or around public housing projects | Peaceful Conflict and Violence Prevention Curriculum | [underlined: Time] | [underlined: Treated] | [underlined: Control] | [underlined: p]
| Intervention Group | | [underlined: Exclusion criteria]: | [underlined: Level:] primary | Pretest | 1.4 (2.9) | 1.1 (2.0) | 0.31
| Initial 292, actual 233 (80%) | | [underlined: Moderating/mediating factors] | [underlined: Kind of program:] conflict resolution | Post test | 1.1 (2.2) | 1.2 (2.4) | 0.63
| Control Group | | [underlined: Outcome 1: violence] | [underlined: Mechanism of delivery] | A group x time interaction was found indicating that the differences between the groups were not consistent from pretest to posttest.
| Initial 412, actual 330 (80%) | | [underlined: Measure]: Use of violence in the previous 30 days, assessed on a 5-item scale ranged from 0 to 20. | Didactic and cognitive, information and role playing | [underlined: Outcome 2]
| [underlined: Age, gender & race groups]: All | | [underlined: Definition]: Frequency of | [underlined: Target population] | Mean (SD) of frequency of fighting requiring medical treatment in previous 30 days (range of scale: 0–20)
| [underlined: Age] | | 1. “Attacked someone with a weapon” or | Middle school students living in or around public housing | [underlined: Time] | [underlined: Treated] | [underlined: Control] | [underlined: p]
| 11 | 235 | 2. “used weapon, force or strong-arm methods to get money” | [underlined: Setting where intervention took place] | Pretest | 0.28 (0.81) | 0.14 (0.50) | 0.01
| 12 | 320 | [underlined: Type:] assault, robbery | Taught in Health Education classes | Post test | 0.17 (0.57) | 0.17 (0.56) | 0.97
| 13 | 126 | [underlined: Circumstance]: Not specified | [underlined: Setting where subjects were recruited] | Theory Used: Social Cognitive Theory
| 14 | 22 | [underlined: Proactive/reactive]: 1, not stated | Middle schools
| [underlined: Gender] | | [underlined: Weapon used]: not specified | [underlined: Person delivering program]
| M | 344 | [underlined: Victim-offender relationship]: not specified | Same African American male instructor
| F | 360 | [underlined: Outcome 2: Adverse health] | [underlined: Time period/duration/frequency]
| [underlined: Race] | | Frequency of fighting requiring medical treatment | 50 minutes, once weekly for 13 weeks
| African American 88.7% | | [underlined: Outcome 3: Effectiveness]
| | | Reduction in violence as determined by post test
| | | [underlined: Outcome 4: Safety]
| | | Not studied
Record # | Study Quality | Time/Place | Prevention Intervention: Definition and characteritic | Findings
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
5758 | [underlined: Study Design:] Single Group Before-after Intervention Study | [underlined: Time (begin, end):] Three school years: 1998-1999, 1999-2000, and 2000-2001 | [underlined: Description of Program] | Primary objective was to reduce family conflict and improve classroom behavior.
Dykeman 2003 J Instructional Psychology | [underlined: Individual study quality score] | [underlined: Place (city, state):] Not specified. Author is at Roosevelt University, Chicago | Conflict resolution model of family-systems intervention for individual parent-child dyads. | | [underlined: Mean ± SD]
| Poor (lack of a control group and >20% incomplete follow-up) | [underlined: Inclusion criteria]: Students from recently dissolved families who were referred by teachers for special education assessment because of recent episodes of disruptive classroom behavior. | [underlined: Name of program] | [underlined: Baseline]: | 1.73 ± .88
| [underlined: Sample size (initial and actual)]: | [underlined: Exclusion criteria]: Those who did not complete treatment and follow-up. | None specified. | [underlined: 6-moths follow-up]: | 133 ± .90
| Initial: 21 | [underlined: Moderating/mediating factors] | [underlined: Level:] Secondary | 2-tailed paired samples t-tests to compare pre-test with follow-up:
| Actual: 15 | None specified. | [underlined: Kind of program:] conflict resolution | t (14)= 1.70; p =.11.
| [underlined: Age, gender & race groups of actual sample]: | [underlined: Outcome 1: physical aggression] | [underlined: Discussion topics]: | No effects for physical aggression.
| [underlined: Mean± SD age]: | [underlined: Measure]: frequency of physical aggression acts as measured by subscale of the Conflict Tactics scale (self-report) at 6 month follow-up | (1) how to appraise and interpret antecedents of conflict, | [underlined: Note]: improvement in teacher-reported classroom behavior (Chi-square (1) = 5.40, p < .05).
| 13.1 years ± 5.8 months | [underlined: Definition]: frequency of throwing objects at a person, pushing/shoving, hitting, and other physical aggression acts. | (2) how to reinterpret a provocation,
| [underlined: Gender]: | [underlined: None of these are specified below]: Type, Circumstance, Proactive/reactive, Weapon used, Victim-offender relationship | (3) how to solve problems, and
| 13 boys, 2 girls | [underlined: Outcome 2: Adverse health] | (4) how to include others in the resolution of a disagreement.
| [underlined: Ethnicity]: | Not studied | [underlined: Mechanism of delivery]
| 8 Caucasians | [underlined: Outcome 3: Effectiveness] | • Teachers conducting student training.
| 4 Hispanics, and | Also examined verbal aggression and use of conflict resolution. Both from Conflict Tactics scale. | • Parent education.
| 3 African-Americans | [underlined: Outcome 4: Safety] | [underlined: Target population]
| | Not studied | Students from 5 junior high schools with behavior problems and whose parents are recently divorced or separated.
| | | [underlined: Setting where intervention took place]
| | | Community agency.
| | | [underlined: Setting where subjects were recruited]
| | | Middle school
| | | [underlined: Person delivering program]
| | | Community agency counselors.
| | | [underlined: Time period/duration/frequency]
| | | Once weekly for 90 minutes. Average length of treatment= 3 months ± 3.2 weeks.
Record# | Study Quality | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
5796 | [underlined: Study Design]: Nonrandomized controlled trial | [underlined: Time (begin, end):] Not specified | [underlined: Description of Program] | The purpose of this study was to provide a benchmark for the expected impact of a two-year intensive, high quality primary prevention program aimed at the promotion of [underlined: social competence].
Elias 1991 Am J Ortho-psychiatry | [underlined: Individual study quality score] | [underlined: Place (city, state):] New Jersey | A 2-year intervention program implemented in grades 4 and 5 with outcome measured in grades 9–11. | Mean Scores on Primary Variables
| Poor (Groups are not comparable at baseline) | [underlined: Study Population:] Students from four different elementary schools | [underlined: Name of program] | Boys
| [underlined: Sample size (initial and actual)]: | [underlined: Inclusion criteria:] Students in their last two years of elementary school (grade 4 and 5) | Improving Social Awareness-Social Problem Solving Project (ISA-SPS) | | E | E2 | E1 | C
| Three cohorts were studied: | [underlined: Exclusion criteria:] Not specified | [underlined: Level:] Primary | Striking/threatening other students | .69 | .71 | .67 | .59
| 1. E1: students who received intervention in 2 high fidelity schools; | [underlined: Moderating/mediating factors] | [underlined: Kind of program] | Attack w/ intent to injure | .37 | .41 | .33 | .46
| 2. E2: students who received intervention in 2 moderate fidelity schools; | Two levels of school fidelity | Social decision-making, problem-solving, and social awareness skills | Striking/threatening parents | .15 | .15 | .14 | .23
| 3. C: students who received no intervention | [underlined: Outcome 1: violence] | [underlined: Mechanism of delivery] | Girls
| Cohort E is the combination of E1 and E2. | [underlined: Measure]: Antisocial and self-destructive behavior as measured by the National Youth Survey (NYS) and the Youth Self Report rating scale in grade 11, 6 years after the 2-year intervention program. | School curriculum | | E | E2 | E1 | C
| Sample sizes were not given for all or by groups. | [underlined: Definition]: Not specified | [underlined: Target population] | Striking/threatening other students | .77 | .74 | .79 | .76
| [underlined: Age, gender & race groups:] Not specified. | [underlined: Outcome 2: Adverse health] | Grades 4 and 5 students | Attack w/ intent to injure | .68 | .66 | .70 | .79
| | Not specified | [underlined: Setting where intervention took place] | Striking/threatening parents | .04 | .05 | .03 | .05
| | [underlined: Outcome 3: Effectiveness] | School | Discriminant analysis findings:
| | Not specified | [underlined: Setting where subjects were recruited] | 1. For Boys, attack with intent to injure and striking/threatening parents combined with 6 other non physical aggression variables provided a discriminant function significantly discriminated experimental subjects from controls; F(8, 121) = 2.11, p<0.04; R=0.35). The three groups could not be significantly differentiated.
| | [underlined: Outcome 4: Safety] | School | 2. For girls, none of the physical aggressions were entered into the discriminant function
| | Not specified | [underlined: Person delivering program]
| | | Teachers
| | | [underlined: Time period/duration/frequency]
| | | 2 year program with 3 phases: Readiness phase, instructional phase, and application phase
| | | Note: This study did not provide sample sizes and standard errors making it impossible to assess effect size
Record # | Study Quality | | | | Time/Place | Prevention intervention: Definition and characteritic | Findings
Author Year, Jnl | Group(s) and Sample Size | | | | Inclusion/Exclusion Criteria
| | | | | Outcome Definition
5871 | [underlined: Study Design]: Randomized controlled trial. At each school, 7th grade homerooms were randomly assigned to intervention or no-intervention. | | | | [underlined: Time (begin, end):] 1997/98 implementation | Description of Program | RIPP 7 was designed to reinforce and extend the effects of RIPP-6 curriculum. They were testing the hypothesis that students who participated in RIPP-7 would have more positive changes in knowledge, attitudes and behaviors targeted by the intervention.
Farrell 2003 J Child and Family Studies | [underlined: Individual study quality score] | | | | Follow up data collected at 6 and 12 months post completion. | [underlined: Name of program] | Adjusted Rates of violent behavior per 100 students (adjusted for pretest differences, age, and gender).
| • retention rate <80% | | | | [underlined: Place (city, state):] Richmond, Virginia | Responding in Peaceful and Positive Ways – 7^th^ grade (RIPP-7) | [underlined: Adjusted Rates] Rate
| [underlined: Sample size (initial and actual)]: | | | | [underlined: Study Population]: 7^th^ graders at 2 public urban middle schools serving primarily African American youth. These youth had received the RIPP-6 in the 6^th^ grade. | [underlined: Level:] primary | | Control | RIPP | Rate Ratio | 95% CI
| Overall: | | | | [underlined: Inclusion criteria]: 7^th^ graders | [underlined: Kind of program] | [underlined: Posttest] | 3.7 | 2.9 | 1.3 | 0.4–4.0
| Initial: 476 | | | | [underlined: Exclusion criteria]: Special education students | Conflict resolution skills | [underlined: 12 month] | 23.1 | 11.2 | 2.1* | 1.1–3.7
| Pre- & Post: 350 | | | | [underlined: Moderating/mediating factors] | [underlined: Mechanism of delivery] | [underlined: *]p<.05
| 6-month follow-up: 340 | | | | • Knowledge of the intervention | Presented during elective classes | Adjusted Means and effect size estimates for violence behavior frequency scales
| 12-month follow-up: 195 | | | | • Attitudes towards violence and nonviolence | [underlined: Target population] | [underlined: Adjusted means] Effect
| Initial: | | | | [underlined: Covariates] | 7^th^ grade | | Control | RIPP | Effect Size | 95% CI
| Intervention Group (Grp 1): 239 students (10 classrooms) | | | | • Gender and age | [underlined: Setting where intervention took place] | [underlined: Posttest] | 10.90 | 11.01 | -0.11 | -0.20-0.14
| Control Group (Grp 2): 237 students (11 classrooms) | | | | [underlined: Outcome 1: violence] | Middle School | [underlined: 6-month FU] | 10.32 | 10.20 | 0.03 | -0.21–0.27
| [underlined: Age] Overall | | | | [underlined: Measure]: | [underlined: Setting where subjects were recruited] | [underlined: 12-month FU] | 11.16 | 10.57 | 0.10 | -0.11–0.32
| Range: 11.9–15.9 | | | | • Frequency of violent behaviors in past 30 days | Middle School | [underlined: Notes:]
| Mean±SD: 12.8±0.6 | | | | • Self-report scale by Problem Behavior Frequency Scales (6-point scale) | [underlined: Person delivering program] | • No significant impact on disciplinary code violations
| [underlined: Gende]r: | All | Grp1 | Grp2 | [underlined: Definition]: includes weapons, fighting, and assaults. | 2 trained prevention specialists (1 per school) | • Significant intervention effect on disciplinary code violent offenses during the 8^th^ grade year
| Males | 224 | 118 | 106 | [underlined: Type]: undefined violent behavior | [underlined: Time period/duration/frequency]
| [underlined: Race]: overall | | | | [underlined: Circumstance, Proactive/reactive Weapon used, Victim-offender relationship]: Not reported | 12 weekly sessions focused on skill building (intervention group missed an average of 1.1 sessions (SD=1.4); 38% had perfect attendance and 93% missed 3 or fewer)
| 97% African American | | | | [underlined: Outcome 2: Adverse health] | [underlined: Notes if any]
| [underlined: Note]: no significant diffrences between interverntion and control groups on gender, race, age, or family structure at p<0.05. No differences between actual and those who left program | | | | [underlined: Outcome 3: Effectiveness] | Both Schools also had a peer mediation program
| | | | | [underlined: Outcome 4: Safety]
| | | | | Not indicated
Record # | Study Quality | Time/Place | Prevention intervention: Definition and characteritic | Findings
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
2260 | [underlined: Study Design]: | [underlined: Time (begin, end):] Nov 1994 through Mar 1995 | [underlined: Description of Program] | [underlined: Mean Perpetrator Outcome Score - School as the unit of analysis (n=14)]
Foshee 1998 Am J Public Health | Randomized controlled trial: | [underlined: Place (city, state):] A predominantly rural county in eastern North Carolina | [underlined: Name of program]: Safe Dates program | [underlined: (A) Primary Prevention]
| • Randomized on schools | [underlined: Mediating variables:] | [underlined: Level:] Primary and secondary | On 862 adolescents reported not a victim or perpetrator of dating violence at baseline
| • stratified by grade and matched on school size | 1. dating violence norms | [underlined: Kind of program] | [underlined: Sexual violence] | [underlined: Treated] | [underlined: Control] | [underlined: p]
| • treatment subjects exposed to school and community activities | 2. gender stereotyping | 1. Behavioral/Cognitive (Dating violence norms, gender stereotyping) | Baseline | ---- | ---- | ----
| • control subjects exposed to community activities only | 3. belief in need for help | 2. Conflict management skills | 1-month post | 0.01 | 0.04 | ns
| [underlined: Individual Study Quality Score] | 4. awareness of services | [underlined: Mechanism of delivery] | [underlined: Violence in current relationship]
| • Retention rate: 81% | 5. help seeking | School Component: | Baseline | ---- | ---- | ----
| • No blinding | 6. conflict management | 1. A theater production performed by peers | 1-month post | 0.01 | 0.03 | ns
| • No intent-to-treat analysis | 7. response to anger | 2. A 10-session curriculum by teachers who had 20 hrs training | [underlined: Assessment of the mediating factors on outcomes – Adolescent as unit of analysis]
| [underlined: Sample size (initial and actual)]: | [underlined: Outcome 1: violence] | 3. A poster contest | On 862 adolescents
| School: | [underlined: Measures] | Community Component: | No significant association found.
| • 14 schools: 7 treatment and 7 matched control schools | 4 measures on perpetration: | 1. Special services (crisis line, support groups, materials for parents) for adolescents in abusive relationships | [underlined: (B) Secondary Prevention]
| Adolescents (Total): | 1. psychological abuse | 2. Community service provider training | On 247 Perpetrators at baseline
| • 2344 eligible adolescents | 2. nonsexual violence | [underlined: Target population] | [underlined: Sexual violence] | [underlined: Treated] | [underlined: Control] | [underlined: p]
| • 1886 (81%) completed baseline questionnaire | 3. sexual violence | School Component: 8th & 9th graders | Baseline | 0.25 | 0.21 | ns
| • 1547 (82% of 1886) completed questionnaire at 1 mo post used in analysis | 4. use of physical force in current relationship | Community Component: workers in social & health services. | 1-month post | 0.07 | 0.18 | p<.10
| • 862 - never a victim/perpetrator | [underlined: Type] | [underlined: Setting where intervention took place] | [underlined: Violence in current relationship]
| • 438 - vicim of dating violence | Sexual assault | School and community | Baseline | 0.31 | 0.20 | ns
| • 247 - perpetrator of violence | [underlined: Circumstance] | [underlined: Setting where subjects were recruited] | 1-month post | 0.17 | 0.16 | ns
| Of the 1700 cohort: | Intimate partners | School | [underlined: Assessment of the mediating factors on outcomes – Adolescent as unit of analysis]
| Age: 11 to 17 years | [underlined: Proactive/reactive] | [underlined: Person delivering program] | On 247 Perpetrators
| Gender: 49% male; 51% female | Not specified | • Peer for the theater production | Treatment condition was associated with sexual violent perpetration (b= -.14, p=.026). This association was mediated by changes in a) perceived negative consequences for using dating violence and b) awareness of perpetrator services.
| Race: 77% white; 19% black | [underlined: Weapon used] | • Teacher for the 10-session curriculum
| No breakdown by groups. | Other | [underlined: Time period/duration/Frequency]
| | [underlined: Victim-offender relationship] | • Curriculum: 10, 45-min/session
| | Intimate partner | • 20 workshops for community service providers
| | [underlined: Outcome 2: Adverse health]
| | None addressed
| | [underlined: Outcome 3: Effectiveness]
| | Change in the 4 outcome measures at 1 month
| | [underlined: Outcome 4: Safety]
| | None addressed
Record # | Study Quality | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
2261 | [underlined: Study Design]: Randomized control trial | [underlined: Time (begin, end):] Nov 1994-March 1995; questionnaires completed in May 1996 | [underlined: Description of Program] | To determine whether the positive short-term effects of the Safe Dates program were maintained at 1-year follow-up.
Foshee 2000 Am J Public Health | [underlined: Individual study quality score] | [underlined: Place (city, state):] Predominantly rural county in eastern N. Carolina | [underlined: Name of program] | [underlined: Mean Perpetrator Outcome Score - School as the unit of analysis (n=14)]
NOTE: This is the one-year follow-up study of #2260. | 1. RCT: Poor (no intent-to-treat analysis; attrition >20%) | [underlined: Study Population]: Eight and 9^th^ graders | Safe Dates Program | [underlined: (A) Primary Prevention]
| [underlined: Sample size (initial and actual): School] | [underlined: Inclusion criteria]: Enrolled in 8^th^ or 9^th^ grade on September 10, 1994 with assent and parental consent | [underlined: Level] | On 816 adolescents reported not a victim or perpetrator of dating violence at baseline
| • 14 schools: 7 treatment and 7 matched control schools | [underlined: Exclusion criteria]: none | Primary and secondary | [underlined: Sexual violence] | [underlined: Treated] | [underlined: Control] | [underlined: p]
| [underlined: Adolescents (Total)] | [underlined: Moderating/mediating factors] | [underlined: Kind of program] | Baseline | ---- | ---- | ----
| • 2344 elgible adolescents | Dating violence norms | 1. Behavioral/Cognitive | 1-year post | 0.05 | 0.07 | ns
| •1886 (80.5%) completed baseline questionnaires | Gender stereotyping | 2. Conflict management skills | [underlined: Violence in current relationship]
| • 1700 (90% of 1886) completed questionnaires at 1 month | Conflict management skills | [underlined: Mechanism of delivery] | Baseline | ---- | ---- | ----
| •1439 (76% of 1886) completed questionnaires at 1 year used in analysis | Beliefs about need for help | School activities: | 1-year post | 0.05 | 0.08 | ns
| • 816 - never a victim/perpetrator | Awareness of community services | 1. Theater production | [underlined: Assessment of the mediating factors on outcomes – Adolescent as unit of analysis]
| • 398 - vicim of dating violence | Help-seeking behaviors | 2. 10-session curriculum | On 862 adolescents
| • 225 - perpetrator of violence | [underlined: Outcome 1: violence] | 3. Poster contest | No significant association found.
| Of the 1439 cohort: | 1. Measure | Community activities | [underlined: (B) Secondary Prevention]
| Gender: 51% female, 49% male | 2. Psychological abuse | 1. Services for adolescents in abusive relationships | Of 225 perpetrators at baseline
| Race: 20% black | 3. Physical violence | 2. Service provider training | [underlined: Sexual violence] | [underlined: Treated] | [underlined: Control] | [underlined: p]
| No breakdown by groups. | 4. Sexual violence | [underlined: Target population] | Baseline | 0.22 | 0.23 | ns
| | 5. Perpetrator in current relationship | School: eighth and ninth graders | 1-year post | 0.15 | 0.12 | ns
| | [underlined: Type]: Dating violence | Community: service providers | [underlined: Violence in current relationship]
| | [underlined: Circumstance]: Dating | [underlined: Setting where intervention took place] | Baseline | 0.31 | 0.20 | ns
| | [underlined: Proactive/reactive]: Not specified | School and community | 1-year post | 0.15 | 0.12 | ns
| | [underlined: Weapon used]: Not specified | [underlined: Setting where subjects were recruited] | [underlined: Assessment of the mediating factors on outcomes – Adolescent as unit of analysis]
| | [underlined: Victim-offender relationship]: dates | School | Of the 225 perpetrators,
| | [underlined: Outcome 2: Adverse health] | [underlined: Person delivering program] | Treatment group adolescents in the perpetrator subsample, compared with control group adolescents, reported using less destructive responses to anger (p=.02) and were more aware of perpetrator services (p=.06).
| | Not addressed | Peers for theater production
| | [underlined: Outcome 3: Effectiveness] | Teacher for curriculum
| | Change in the 4 outcome measures at 1 year | [underlined: Time period/duration/frequency]
| | [underlined: Outcome 4: Safety] | Curriculum: 10 45-minute sessions
| | Not addressed | No other details provided in this article (see #2260)
| | | [underlined: Notes if any]
Record # | Study Quality | | | | Time/Place | Prevention intervention: Definition and characteritic | Findings
Author Year, Jnl | Group(s) and Sample Size | | | | Inclusion/Exclusion Criteria:
| | | | | Outcome Definition
5995 | [underlined: Study Design:] Randomized controlled trial with post assessment at time of discharge from facility, at 9 months after admission, and at 6 months post discharge from facility. | | | | [underlined: Time (begin, end):] Not specified | [underlined: Description of Program] | The main hypothesis was that program participants (A) would be found at the follow up assessment (15 months after admission to the project) to have made significantly more positive changes compared to the controls in: drug use, illegal offenses, violent illegal offenses, selling drugs, school problems
Friedman 2002 J Child and Adolescent Substance Abuse | [underlined: Individual study quality score] | | | | [underlined: Place (city, state):] Philadelphia, PA | Triple modality social learning program in a classroom, designed as a drug prevention/early intervention program | Comparison of program participants with control subjects on degree of reduction in problem behavior, time of follow up evaluation, using multiple regression analysis (dependent variable is degree of violent offenses, covariates listed under moderating/mediating factors):
| • no intent-to-treat analysis | | | | [underlined: Study Population:] Inner city, low SES, court-adjudicated male adolescents in a residential treatment center | [underlined: Name of program] | t- value comparing Group A and Group C based on 201 subjects was 0.44. (For an N of 200, a t value of 1.97 or better is significant at the .05 level of confidence
| [underlined: Sample size (initial and actual):] | | | | [underlined: Inclusion criteria:] | Intervention uses 3 programs | Conclusion:
| Actual | | | | • New admission | 1) Botvin Life Skills Training Model (LST) | • The AV program has the potential to be effective in reducing violent behavior.
| Total: 201 (84% of original) | | | | • Male | 2) The Prothrow-Stith Anti-Violence Program (AV) | • Triple-modality classroom program that was utilized did not show a significant advantage for reducing the degree of illegal or violent behavior.
| Intervention Group (Grp A): 110 | | | | • 13–18 years of old | 3) Values Clarification (VC)
| Cntrol Group (Grp C): 91 | | | | • Committed by Family Court | [underlined: Level:] secondary
| [underlined: Age, gender & race groups:] | | | | [underlined: Exclusion criteria:] | [underlined: Kind of program]
| | All | GrpA | GrpC | • Youth went AWOL from the residential facility | 1) Cognitive behavioral social learning model for understanding the effects of drugs on health and behavior
| Mean Age | 15.5 | 15.5 | 15.5 | • Youth were considered unmanageable in the classroom setting | 2) Social learning model for controlling tendencies toward violence
| SD | | 1.1 | 1.1 | • Youth were removed from the facility and committed elsewhere | 3) Social learning model for clarifying values and developing new values
| Gender 100% male | | | | • Youths' parent failed to consent | [underlined: Mechanism of delivery]
| Race | | % | % | [underlined: Moderating/mediating factors] | 55 classroom sessions scheduled; average of 34.2 classroom sessions attended
| Black | | 76.4 | 69.3 | • Age | [underlined: Target population]
| White | | 13.6 | 16.7 | • years of education | Adolescents who had been convicted of at least one illegal offense of sufficient seriousness to warrant a court procedure, and may have had early involvement in the use of “gateway” drugs or other illicit substances. The majority had ben subject, before admission, to multiple risk factors.
| Puerto Rican | | 7.3 | 8.8 | • being African-American | [underlined: Setting where intervention took place]
| Asian | | 1.8 | 2.7 | • being Caucasian | Residential facility and classroom
| Attrition Analysis showed for Group A that more white youth were retrieved for follow up. The retrieved group had a lesser degree of school problems. For Group C, more retrieved youth grew up in intact families, more youth had part-time employment, and the retrieved youth reported less illegal behavior at baseline. | | | | • occupational head of household | [underlined: Setting where subjects were recruited]
| | | | | • growing up with biological parents | Residential Treatment Program
| | | | | • having been physically abused | [underlined: Person delivering program]
| | | | | • problem behavior and attitudes | Teacher, not specified
| | | | | [underlined: Outcome 1: violence] | [underlined: Time period/duration/frequency]
| | | | | [underlined: Measure:] Violent Behavior measured at 15 months follow-up using a score based on a formula developed by Turner and Rutledge (1987). It was derived by assigning various weights to 8 of the 20 illegal offenses included in the “Legal” problem section of the ADAD (Adolescent Drug Abuse Diagnosis) | 20 sessions of LST during a 4 week period.
| | | | | [underlined: Definition:] points determined by system looking at: | 20 sessions of AV.
| | | | | • assault or gang fighting (1 pt) | 15 of VC
| | | | | • weapons offenses (1.5 pt) | Intervention group attended an average of 34.2 classroom sessions of 55 sessions that were scheduled.
| | | | | • robbery (2 pts) | [underlined: Notes if any]
| | | | | • arson or rape or reckless endangerment (3 pts) | 16% attrition rate between the post assessment and the follow up assessment in the community.
| | | | | • homicide/manslaughter (5 pts) | Those who attended more of the AV sessions and who also were rated as showing more critical thinking about problems, were found at follow up to report significantly less violent behavior. On the other hand, those who were rated as “offering more comments” during these sessions were found at follow up to report significantly more violent behavior.
| | | | | [underlined: Type:] assault, gang fighting, weapon offense, robbery, arson, rape, reckless endangerment, and homicide.
| | | | | [underlined: Circumstance, Proactive/reactive:] Not report
| | | | | [underlined: Weapon used]
| | | | | Weapon offenses included in point system.
| | | | | [underlined: Victim-offender relationship]
| | | | | Not reported
| | | | | [underlined: Outcome 2: Adverse health]
| | | | | Not reported
| | | | | [underlined: Outcome 3: Effectiveness]
| | | | | As compared to Group C, Group A at 15 months assessment after admission to the project would have made significantly more positive change, to 6 key outcomes: drug use, alcohol use, illegal offenses committed, violent illegal offenses committed, selling of drugs, school problems.
| | | | | [underlined: Outcome 4: Safety]
| | | | | Not reported
Record# | Study Quality | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
4048 | [underlined: Study Design]: Cross-sectional study | [underlined: Time (begin, end):] 1991-1992 school year | [underlined: Description of Program] | To evaluate whether school-based metal detector programs reduce violence behaviors in schools and to and from schools.
Ginsberg 1993 MMWR | [underlined: Individual study quality score] | [underlined: Place (city, state):] New York, NY | [underlined: Name of program] | [underlined: Outcome 1 Violence behaviors: Involved in a physical fight at least once during the 1991-92 school year.]
| Poor (potential confounders no controlled for). | [underlined: Study Population]: Sample of 9^th^–12^th^ grade students of all NYC public high schools | School-based metal detector program | (A) by Site
| [underlined: Sample size (actual only)]: | [underlined: Inclusion criteria]: None | [underlined: Level:] Primary | Factor | % (95% CI)
| Overall: | [underlined: Exclusion criteria]: None | [underlined: Kind of program] | To/from School | 9.2 ( 6.3–12.1)
| 1399 students | [underlined: Moderating/mediating factors] | Random, weekly scans using hand-held metal detectors | Inside School | 7.7 ( 5.0–10.4)
| 15 schools | None | [underlined: Mechanism of delivery] | Anywhere | 24.7 (21.5–28.0)
| Intervention: | [underlined: Outcome 1: violence] | On entry to school building | (B) by Metal detector program
| 243 students | [underlined: Measure/Definition]: Involved in a physical fight at least once during the school-year. | [underlined: Target population] | | Metal detector program | | No program
| 3 schools | [underlined: How measured]: Self-reported | New York City youth | Behavior | % | (95%CI) | % | (95%CI)
| Control: | [underlined: All other characteristics]: Not specified | [underlined: Setting where intervention took place] | Anywhere | 26.2 | (14.4–38.0) | 24.4 | (21.5–27.3)
| 1156 students | [underlined: Outcome 2: Effectiveness] | High schools | To/From school | 9.4 | ( 6.4–12.3) | 9.1 | ( 5.6–12.6)
| 12 schools | Prevalence of violent behaviors | [underlined: Setting where subjects were recruited] | Inside school | 7.5 | ( 0.4–14.5) | 7.8 | ( 4.9–10.7)
| [underlined: Age, gender & race groups]: not specified | [underlined: Outcome 3: Adverse Health] | High schools
| | Not studied | [underlined: Person delivering program]
| | [underlined: Outcome 4: Safety] | Security officers
| | Not studied | [underlined: Time period/duration/frequency]
| | | Weekly, for one school year
| | | [underlined: Notes if any]
| | | Students were scanned at random
Record # | Study Quality | Time/Place | Prevention Intervention: Definition and Characteristic | Finding
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
6187 | [underlined: Study Design]: Retrospective single group study-before and after time series. | [underlined: Time (begin, end):] 1984-1989 | [underlined: Description of Program] | The purpose of the study was to examine recidivism rates of adolescent rapists incarcerated at a state juvenile correctional facility This study examined the effectiveness of a treatment program for serious sex offenders.
Hagan 1994 Int J Offender Therapy & Comparative Criminology | [underlined: Individual study quality score] | [underlined: Place (city, state):] Wales, Wisconsin | The program used group process as the cornerstone. Most treatment occurred in groups; most issues related to being a delinquent and sex offender, using techniques that were both confrontational and supportive. | Number and percent during 2-year post-discharge
| Poor (no control group). | [underlined: Study Population:] Adolescent male convicted of a serious sexual assault and perpetrated crimes of sexual assault against members of the opposite sex. All had a conduct disorder of an aggressive type. | [underlined: Name of program] | | N | %
| [underlined: Sample size (initial and actual)]: 50 | [underlined: Inclusion criteria]: See above | Stout Cottage Serious Sex Offenders Program (SSOP) | Committed additional sexual assault
| [underlined: Age, gender & race groups]: | [underlined: Exclusion criteria]: Not specified | [underlined: Level]: Tertiary | | 5/50 | 10%
| Age: Not specified | [underlined: Moderating/mediating factors] | [underlined: Kind of program] | Convicted of another crime perpetrated against a person
| Gender: 100% males | Not specified | Group therapy process | | 14/50 | 28%
| Race: Not specified | [underlined: Outcome 1: violence] | [underlined: Mechanism of delivery] | The 10% and 28% can be considered as failure rates of the program.
| | [underlined: Measure]: recidivism rate of sexual assaults and criminal activities during 2-year post discharge | Group therapy, open entrance open exit. Average of 8 youth present in each group.
| | [underlined: Definition]: Crime perpetrated against a person included robbery, battery, disorderly conduct, and sexual assault | [underlined: Target population]
| | [underlined: Outcome 2: Adverse health] | Convicted adolescent male rapists
| | Not specified | [underlined: Setting where intervention took place]
| | [underlined: Outcome 3: Effectiveness] | Ethan Allen School-secure residential facility for male juvenile offenders
| | Failure rate in terms of reincarceration or success rate of avoiding reincarceration | [underlined: Setting where subjects were recruited]
| | [underlined: Outcome 4: Safety] | Ethan Allen School, part of the Department of Health and Social Services, Division of Youth Services.
| | Not specified | [underlined: Person delivering program]
| | | A social worker, a consulting psychologist, and non-degreed youth counselors
| | | [underlined: Time period/duration/frequency]
| | | Group therapy was for 3 one-hour sessions per week. On average, it took subjects 8 months to complete the group process.
Record # | Study Quality | Time/Place | Prevention Intervention: Definition and Characteristic | Finding
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
2563 | [underlined: Study Design]: Nonrandomized control trial | [underlined: Time (begin, end):] 1989-1990 school year | [underlined: Description of Program] | Reports preliminary findings of a program to train African-American adolescents in social skills, an approach which shows promise as a means of preventing violence.
Hammond 1991 J Health Care for the Poor and Underserved | [underlined: Individual study quality score] | [underlined: Place (city, state):] Dayton, Ohio | [underlined: Name of program] | School Suspensions Attributed to Violence*
| Poor (potential confounders not controlled) | [underlined: Study Population:] Selected high risk African American middle school students | Positive Adolescents Choices Training (PACT) | Groups | Beginning of Training | End of Training
| [underlined: Sample size (initial and actual)]: Overall: 28 | [underlined: Inclusion criteria]: Youth were selected by teachers on the basis of such criteria as deficiencies in skills needed to interact with peers, behavior problems (particularly aggression), or history of victimization by violence. | [underlined: Level:] Secondary | Intervention | 2/15 (13%) | 0/15 (0%)
| Intervention Group (Grp 1): 15 | [underlined: Exclusion criteria]: Not specified | [underlined: Kind of program] | Partially trained | 2/ 6 (33%) | 1/ 6 (16%)
| Control Group (Grp 2): 13 | [underlined: Moderating/mediating factors] | Social skills training-behavioral component | Control | 3/13 (23%) | 7/13 (54%)
| [underlined: Age, gender & race groups]: | Not specified | [underlined: Mechanism of delivery] | P-value | 0.57 | 0.003
| Age: Middle School students | [underlined: Outcome 1: violence] | Small-group training-composed of 10–12 youths | P (Int vs Con) | 0.64 | 0.001
| Gender: Not specified | Measure: Suspension attributed to violence | [underlined: Target population] | *Time period of data not specified.
| Intervention Group | Definition: Not specified | Selected high risk African American middle school students
| African-American: 93% (14) | Type: Not specified | [underlined: Setting where intervention took place]
| White: 6% (1) | Circumstance: Not specified | School
| (The white student was excluded in analysis.) | Proactive/reactive: Not specified | [underlined: Setting where subjects were recruited]
| Control Group | Weapon used: Not specified | School
| Race: Not specified | Victim-offender relationship: Not specified | [underlined: Person delivering program]
| | [underlined: Outcome 2: Adverse health] | Two African-American doctoral-level clinical psychology students
| | Not studied | [underlined: Time period/duration/frequency]
| | [underlined: Outcome 3: Effectiveness] | Each group had 37 or 38 training sessions lasting a class period (about 50 minutes)
| | Reduction in suspension attributed to violence | [underlined: Notes if any]
| | [underlined: Outcome 4: Safety]
| | Not studied
Record # | Study Quality | | | | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | | | | Inclusion/Exclusion Criteria
| | | | | Outcome Definition
6221 | [underlined: Study Design]: Randomized controlled trial (Two youth bureaus were randomly assigned, one to treatment one to control) | | | | [underlined: Time (begin, end):] Not stated | [underlined: Description of Program] | The principal aim of this study was to determine the effectiveness of a data-based, early intervention strategy designed to interrupt the development of deviance, including substance abuse in youth from largely African American inner-city neighborhoods who were considered to be at high risk for progression in deviance on the basis of early signs of aberrant behavior..Violence was one of the outcomes evaluated as a section of a comprehensive youth questionnaire.
Hanlon 2002 J Youth and Adolescence | [underlined: Individual study quality score] | | | | [underlined: Place (city, state):] Baltimore, Maryland | Individual counseling, mentoring, and help with school problems, basic learning and study skills, refinement of social and life coping skills, cultural heritage, enhancement of self esteem, conflict resolution, avoidance of substance abuse, HIV/AIDS education and prevention, community health and recreational resources. Field trips, holiday celebrations Informal discussions with parents and parent child social events. | Poisson regression analysis in which the dependent variable is violent behavior:
| • attrition rate not reported | | | | [underlined: Study Population]: Inner-city youth at high risk of adopting a deviant lifestyle. | [underlined: Name of program:] An early community-based intervention for the prevention of substance abuse and other delinquent behavior. | [underlined: Risk Factor] | χ^2^ | p
| • validity of instrument not addressed | | | | [underlined: Inclusion criteria]: | [underlined: Level:] Secondary | 1 Prior instance of violence | 13.0 | 0.0003
| [underlined: Sample size (initial and actual):] | | | | Informed consent of youth and caregiver that met any 1 or more of the 3 criteria: | [underlined: Kind of program] | 2 Peer deviance | | 0.0045
| Total: | | | 428 | 1. Known or admitted early experimentation with alcohol or drugs | Behavioral cognitive and skill building | 3 School problematic behavior | | 0.0067
| Intervention Group: | | | 235 | 2. History of delinquency or other deviant behavior, including criminal activity, incorrigibility and precocious sexual behavior | [underlined: Mechanism of delivery] | 4 age by clinic effect | | 0.0016
| Control Group: | | | 193 | 3. Expulsion from school or other indication of problematic school behavior. | Individual counseling and group mentoring | Note: χ^2^ values were not provided for other effects.
| [underlined: Age] | | | | [underlined: Exclusion criteria]: Primary Problem of Substance abuse | [underlined: Target population] | Peer deviance includes peer expulsion from school, close friends arrested, convicted, paroled and /or incarcerated
| | Intv | Con | Total | [underlined: Moderating/mediating factors] | Inner-city youth at high risk of adopting a deviant lifestyle. | The study states that:
| Range | | | 9–17 | • Welfare involvement | [underlined: Setting where intervention took place] | 1. Age was also a highly relevant characteristic for most outcome measures - older subjects reporting relatively greater substance abuse, sexual behavior, and delinquent activity, including violent activity, along with a greater incidence of arrest at follow up.
| Mean | 13.0 | 13.6 | 13.3 | • Parental separation | Community-based “Youth Bureaus” clinic | 2 The finding that poor parenting practices tended to be related to involvement in violent activity at follow up is consistent with the observation of others that poor parenting is one of the most important risk factors for violence.
| SD | | | 1.91 | • Parental history of incarceration | [underlined: Setting where subjects were recruited] | 3. in the present study peer deviance was a prominent predictor of both marijuana use and number of types of delinquent and violent activity engaged in at follow-up
| [underlined: Gender] | | | | • Deviant behavior of peers | Youth were referred by family (50%), school (26%), community service agencies (17%) or Maryland Dept of Juvenile Justice (6%). | However there is no quantification of the conclusions above except as noted in the initial chart with p values related to peer deviance
| # Male | 125 | 126 | 251 | • School attendance | [underlined: Person delivering program]
| %Male | 53 | 65 | 59 | • School related problems | • Existing clinic personnel who were trained in a case management approach involving needs assessment, planning and review of mutually agreed upon treatment goals and advocacy referral procedures.
| P=0.012 | | | | • Crime related deviant behavior | • Counselor: Clinic staff trained as case manager
| [underlined: Race] | | | | • Arrest history | • Mentor: :young African American college students
| # (%) AfrAm | | 417(97.4) | | • Weapon carrying | • Part time teachers
| # (%) White | | 11( 2.6) | | • Sexual activity | [underlined: Time period/duration/frequency]
| | | | | [underlined: Outcome 1: violence] | 4–5 days per week after school and weekends over about 1 year or more
| | | | | [underlined: Measure] Self report physical violence behavior through “Youth Questionnaire” developed by researchers on vulnerability to substance abuse and family background and early development of methadone maintenance clients and children. At 1-year follow-up, only past 6-months' self-report information was obtained.
| | | | | [underlined: Definition] Physical assault, mugging, robbery with a weapon, arson, participating in a gang fight and shooting at someone
| | | | | [underlined: Type:] aggravated assault, non aggravated assault, robbery, gang fight
| | | | | [underlined: Circumstance, Proactive/reactive Weapon used, Victim-offender relationship]: not specified
| | | | | [underlined: Outcome 2: Effectiveness]
| | | | | See outcome measure
| | | | | [underlined: Outcome 3: Adverse Health]
| | | | | Not stated.
| | | | | [underlined: Outcome 4: Safety]
| | | | | Not stated.
Record # | Study Quality | | | Time/Place | Prevention intervention: Definition and characteritic | Findings
Author Year, Jnl | Group(s) and Sample Size | | | Inclusion/Exclusion Criteria
| | | | Outcome Definition
2588 | [underlined: Study Design:] Partially randomized controlled study. | | | [underlined: Time (begin, end):] Year not specified (program was piloted tested in spring of 1995) | [underlined: Description of Program] | The All Stars character education and problem prevention program seeks to impact on mediating variables in order to impact on sexual activity, substance use, and violent behavior of middle school students
Harrington 2001 Health Education and Behavior | 14 middles schools: | | | T1 Pretest – Sept/Oct | [underlined: Name of program] | Mean Violence as a function of Time, Condition, and Ethnicity
| 8 schools received treatment (5 by specialists and 3 by school teachers); | | | T2 Post test-May | All Stars character education and problem behavior prevention program | [underlined: African American]
| 6 schools did not received treatment. | | | T3 Follow up – 1 year later | [underlined: Level:] primary | [underlined: Condition] | T1 | T2 | T3
| [underlined: Individual study quality score] | | | [underlined: Place (city, state):] Largest cities in Midwestern state | [underlined: Kind of program] | Control | 1.35 | 1.40 | 1.59
| Poor (improper randomization scheme; attrition >20%) | | | [underlined: Study Population]: Sixth or 7th grade students | Seeks to modify targeted mediating variables based on Hansen's review of risk and protective factors found to predict alcohol, tobacco, and drug use. | Specialist | 1.41 | 1.38 | 1.54
| [underlined: Sample size (initial and actual)]: | | | [underlined: Inclusion criteria]: Consent signed | [underlined: Mechanism of delivery] | Teacher | 1.35 | 1.32 | 1.27
| Initial pre test: 2289 students | | | [underlined: Exclusion criteria]: None identified | • Whole classroom debates, games, and general discussion | [underlined: White]
| Completed all posttest –1655 (72%) | | | [underlined: Moderating/mediating factors] | • Small group sessions outside of class | [underlined: Condition] | T1 | T2 | T3
| Gp 1: Intervention: 629 | | | • Positive ideals | • One on one sessions between instructor and student | Control | 1.25 | 1.27 | 1.37
| Gp 2: Control: 739 | | | • Beliefs in conventional norms | • Homework to promote interaction between students and parents | Specialist | 1.26 | 1.31 | 1.40
| Pattern of attrition did not result in a smaple markedly different from the population of interest. | | | • Commitments not to use substances | [underlined: Target population] | Teacher | 1.28 | 1.27 | 1.42
| [underlined: Age, gender & race groups]: | | | • Bonding to school | Middle school students | [underlined: Hispanic]
| Total sample at baseline: | | | [underlined: Outcome 1: Violence] | [underlined: Setting where intervention took place] | [underlined: Condition] | T1 | T2 | T3
| [underlined: Age:] | Mode: | 12 years | [underlined: Measure]: mean of 10 items selected from extant delinquency scales | School | Control | 1.19 | 1.18 | 1.34
| [underlined: Gender:] | Female | 55% | [underlined: Definition]: violence towards other persons | [underlined: Setting where subjects were recruited] | Specialist | 1.28 | 1.34 | 2.07
| [underlined: Race:] | White | 69% | [underlined: Type, Circumstance, Proactive/ reactive, Weapon used Victim-offender relationship], not specified | School | Teacher | 1.24 | 1.22 | 1.22
| | Afr Am | 25% | [underlined: Outcome 2: Effectiveness] | [underlined: Person delivering program] | • Only the time effect was significant for violence F(2, 1651)-14.68, p<.001
| | Hisp | 6% | changes in four targeted mediators and sexual activity, substance use, and violent behavior | Program specialists or classroom teachers | • Mean violence did not differ from pretest to posttest but evidenced a clear increase across all conditions from posttest to follow-up.
| | | | [underlined: Outcome 3: Adverse health] | [underlined: Time period/duration/frequency] | • Time, condition and ethnicity interaction was significant, F(8, 3290)-3.12, p<0.001
| | | | Not adddressed | Program implemented from about October – May. No total hours / sessions specified. | • African American, Hispanic and White students showed no change in violence from pre to post test. From post test to follow-up, Hispanic students remained stable, while African Americans decreased slightly and Whites increased somewhat.
| | | | [underlined: Outcome 4: Safety]
| | | | Not specified
Record # | Study Quality | | Time/Place | Prevention intervention: Definition and characteritic | Findings
Author Year, Jnl | Group(s) and Sample Size | | Inclusion/Exclusion Criteria
| | | Outcome Definition
117 | [underlined: Study Design:] Nonrandomized control trial (Seattle Social Development Project Intervention) | | [underlined: Time (begin, end):] 1981-1993 | [underlined: Description of Program] | To examine the long-term effects of an intervention combining teacher training, parent education, and social competence training for children during the elementary school grades on adolescent violent behavior at age 18 years
Hawkins 1999 Arch Pediatr Adolesc Med | [underlined: Individual study quality score] | | [underlined: Place (city, state):] Seattle, WA | [underlined: Name of program] | [underlined: Full]=full intervention (received intervention from grades 1–6)
| Fair (questionable comparability of study and control groups) | | [underlined: Study Population:] Elementary school students | Not specified | [underlined: Late]=late intervention (received intervention only in grades 5–6)
| [underlined: Baseline sample size (group that received intervention)] | | [underlined: Inclusion criteria:] Fifth grade students enrolled in participating schools who had written parental consent to participate in the longitudinal study | [underlined: Level:] Primary | Prevalence of lifetime violence
| Total: | 643 | [underlined: Exclusion criteria:] None specified | [underlined: Kind of program] | Control | Late | Full
| Full intervention | 156 | [underlined: Moderating/mediating factors] | Package of 3 interventions: | 59.7 | 56.4 | 48.3
| Late intervention: | 267 | Not specified | 1. Classroom instruction and management to provide teachers skills in proactive classroom management, interactive teaching, and cooperative learning | Control vs. Full
| Control: | 220 | [underlined: Outcome 1: violence] | 2. Child skill development in alternative solutions to problems with peers | Difference (95% CI) | | p-value
| [underlined: Analysis sample size (group on which outcomes were measured)] | | Measure: reduction in lifetime violent behavior reported at age 18 | 3. Parent intervention to train parents in child behavior management skills | -11.4 (-21.3 to -0.4) | | .04
| Total: | 598 | Definition: Self-reported violent acts with follow-up 6 years after intervention | [underlined: Mechanism of delivery] | Control vs Late
| Full intervention | 149 | [underlined: Type; Circumstance; Proactive/reactive; Weapon used; Victim-offender relationship]: Not specified | All components of intervention package delivered in group setting using a curriculum | Difference (95% CI) | | p-value
| Late intervention: | 243 | [underlined: Outcome 2: Adverse health] | [underlined: Target population] | -3.3 (-12.0 to 6.3) | | .54
| Control: | 206 | Definition of outcome measure(s) | Elementary school students, their parents, and their teachers (enrolled in grade 1, intervention provided in grades 1–6)
| [underlined: Age, gender & race characteristics of Baseline sample] | | Not specified | [underlined: Setting where intervention took place]
| Age: | 5^th^ graders | [underlined: Outcome 3: Effectiveness] | School
| Gender: | | Definition of outcome measure(s) | [underlined: Setting where subjects were recruited]
| Full intervention | 50.6% male | Reduction in violent behavior at age 18 yrs | School
| Late intervention: | 48.7 male | [underlined: Outcome 4: Safety] | [underlined: Person delivering program]
| Control group | 53.6% male | Definition of outcome measure(s) | 1. Classroom instruction and management: Not specified
| Race: | | Not specified | 2. Child skill development: teachers
| Full intervention | 46.8%White | | 3. Parent intervention: not specified
| Late intervention: | 42.7% White | | [underlined: Time frequency/duration]
| Control group | 44.5% White | | 1. Classroom instruction and management: 5 days of inservice training
| | | | 2. Child skill development: Not specified for grades 1–5; in grade 6, 4 hours of training
| | | | 3. Parent intervention: 7-session
| | | | curriculum in grade 1, 5-session
| | | | curriculum in grades 2 and 3, 5-session
| | | | curriculum in grades 5 and 6.
Record # | Study Quality | | | Time/Place | Prevention intervention: Definition and characteritic | Findings
Author Year, Jnl | Group(s) and Sample Size | | | Inclusion/Exclusion Criteria
| | | | Outcome Definition
2644 | [underlined: Study Design]: Randomized Controlled Trial with 4-year follow-up outcome | | | [underlined: Time (begin, end):] Mid 1990's | [underlined: Description of Program] | [underlined: Purpose]: To address the gap in the adolescent substance abuse treatment literature by implementing a randomized clinical trial using MST with adolescent substance abusers and collecting long term follow up assessments.
Henggeler 2002 J Am Acad of Child and Adol Psychiatry | [underlined: Individual study quality score] | | | [underlined: Place (city, state):] Not stated | [underlined: Name of program] | [underlined: Aggressive] | [underlined: MST] | [underlined: Usual]
| • Retention rate <80%) | | | [underlined: Study Population]: Juvenile offenders with substance abuse and dependence. The families were economically disadvantaged. | Multi-systemic therapy (MST) vs. usual community services. | [underlined: Crimes] | [underlined: Mean]±[underlined: SD] | [underlined: Mean]±[underlined: SD] | [underlined: p]
| • no intent-to-treat analysis | | | [underlined: Inclusion criteria:] offenders meeting DSM III-R criteria for substance abuse or dependence | [underlined: Level:] Tertiary - focused on youth offenders | Aggression scale | 0.61±0.90 | 1.36±2.21 | <.05
| [underlined: Sample size (actual)]: | | | [underlined: Exclusion criteria]: None | [underlined: Kind of program] | Annualized Conviction rate | 0.15±0.43 | 0.57±1.80 | <.05
| Initial (T1) 118 | | | [underlined: Moderating/mediating factors] | MST- includes multiple interventions including family therapy, parenting, cognitive behavioral therapies, and medication, as indicated | Multivariate analysis using youth age and T1 marijuana use as covariate showed statistically significant (p<.05) lower recidivism rate in the MST group.
| Actual (T5) 80 (68%) | | | Demographic characteristics | [underlined: Mechanism of delivery] | [underlined: Moderator effects]: No significant moderator effects were obtained. Thus the impact of treatment did not vary as a function of demographic characteristics, comorbid psychopathology, or initial (T1) levels of illicit drug use and criminal behavior.
| Intervention Group (Grp 1): 43 | | | Comorbid psychopathology | Strategic family therapy, structural family therapy, behavioral parent training, and cognitive-behavioral therapies.
| Control Group (Grp 2): 37 | | | Initial T1 levels of illicit drug use | [underlined: Target population]
| [underlined: Age, gender & race groups]: | | | Initial T1 levels of criminal behavior | Juvenile offenders meeting DSM III R criteria for substance abuse or dependence and their families
| | Time 1 | Time 5 | [underlined: Outcome 1: Criminal Behavior] | [underlined: Setting where intervention took place]
| N | 118 | 80 | [underlined: Measure]: 4-year aggressive crimes score - aggregate of items measured in the Self-Report Delinquency (SRD recoded into 3-point Likert scales (0=none, 1=1–3 times, 2=more than 3 times in the past year) and summed to form total Aggressive Crimes score. | Home-based
| [underlined: Age] | 15.7 | 19.6 | [underlined: Definition]: Major assaults, minor assaults, and strong-armed robbery. | [underlined: Setting where subjects were recruited]
| [underlined: Male] | 79% | 76% | [underlined: Circumstance, Proactive/reactive, Weapon used, Victim-offender relationship, Adverse health effects and Safety Outcomes]: Not noted | Not stated
| [underlined: Race] | | | | [underlined: Person delivering program]
| Af Am | 50% | 60% | | Master's level clinicians supervised by a child/adolescent psychiatrist
| White | 47% | 40% | | [underlined: Time period/duration/frequency]
| Other | 3% | 0% | | Average of 46 hours of contact per family over an average of 130 days of treatment. 24/7 availability of therapists.
| Research dropouts did not differ from research completers.
Record # | Study Quality | | | | Time/Place | Prevention intervention: Definition and characteritic | Findings
Author Year, Jnl | Group(s) and Sample Size | | | | Inclusion/Exclusion Criteria
| | | | | Outcome Definition
10598 | [underlined: Study Design:] | | | | [underlined: Time (begin, end):] | [underlined: Description of Program] | To examine the effects of relocating families from high- to low-poverty neighborhoods on juvenile violent crime using data gathered by a randomized housing-mobility experiment.
Ludwig 2001 Quarterly J Economics | Randomized controlled trial - community based trial. Families were randomized into 3 groups: | | | | Identification of families: July-Dec 1997 | [underlined: Name of program] | [underlined: I. Preprogram arrests percents]
| Experimental group families receive housing subsidies, counseling, and search assistance to move to private-market housing in low-poverty census tracts; | | | | Outcomes collected through March 1999 | The Moving to Opportunity (MTO) demonstration is based in 5 cities: Baltimore, Boston, Chicago, Los Angeles, and New York. The study uses data from the Baltimore site. | [underlined: # of arrests] | [underlined: Total] | [underlined: Exp.] | [underlined: Section-8] | [underlined: Control]
| Section-8 only comparison group families receive private-market housing subsidies with no program constraints on relocation choices; | | | | [underlined: Place (city, state):] Baltimore, Maryland | [underlined: Level:] Secondary | | [underlined: (n=336]) | [underlined: (n=148)] | [underlined: (n=92)] | [underlined: (n=96)]
| Control group families received no special assistance under MTO. | | | | [underlined: Study Population:] Teens from families enrolled in the HUD MTO experiment in Baltimore who are considered “at risk” for criminal involvement in postprogram period | [underlined: Kind of program] | One | 9.0% | 9.5% | 9.8% | 7.3%
| [underlined: Individual study quality score] | | | | [underlined: Inclusion criteria:] | Housing-mobility experiment | Two | 2.1% | 3.1% | 0.6% | 2.1%
| • retention rate not reported | | | | • Eligibility to MTO was restricted to low-income families with children who lived in public housing in one of the five poorest census tracts in the city | [underlined: Mechanism of delivery] | 3 or more | 1.2% | 1.0% | 1.6% | 1.0%
| • no blinding of assessments | | | | • For this study, teens must be at least 11 years old but less than 16 years old at time of random assignment into experimental, section-8, or control group | Physical environment change | [underlined: II. EFFECTS OF MTO ON JUVENILE VIOLENT CRIME ARRESTS (*p<0.1 **p<0.05]
| [underlined: Sample Size:] | | | | [underlined: Exclusion criteria:] Children under 11 years old or older than 15 years old | [underlined: Target population] | Intent-to-treat effects (coefficient estimates) for [underlined: incidence] of violent crime (number of violent crime arrests per 100 teens per quarter):
| Total sample: | | | n=336 | [underlined: Moderating/mediating factors] | Teens living in high-poverty neighborhoods who are “at risk” for criminal involvement | | | [underlined: Control] | [underlined: Exp vs.control] | [underlined: Section-8 vs. control]
| Experimental: | | | n=148 | Household characteristics | [underlined: Setting where intervention took place] | [underlined: Risk Group of Interest] | | [underlined: Mean] | [underlined: Coef (SE)] | [underlined: Coef (SE)]
| Section-8: | | | n=92 | • African-American | Community | Total sample (n=336)
| Control group: | | | n=96 | • Female householder | [underlined: Setting where subjects were recruited] | Unadjusted | | 3.0 | -1.0 (0.8) | -1.4 (0.8)*
| [underlined: Age, gender & race groups] | | | | • Householder age | Community | Regression-adjusted | | 3.0 | -1.6 (0.8)** | -1.4 (0.8)*
| [underlined: Total Sample] | | | | • Number of children | [underlined: Person delivering program] | | | [underlined: Regression-adjusted coefficient (SE)]
| [underlined: Age:] | Range 11 – 15 years | | | • Householder w/high school or GED | Housing Authority of Baltimore (HAB) and the Community Assistance Network (CAN) | Teens with no preprogram arrests (n=256) | | 2.2 | -1.0 (0.7) | -1.4 (0.8)*
| [underlined: Gender:] | 157 (46.7%) male | | | • AFDC at baseline | [underlined: Time period/duration/frequency] | Males (n=162) | | 4.3 | -2.9 (1.4)** | -1.9 (1.2)*
| [underlined: Race:] | 327 (97.3%) Af-Am. | | | • Past 6 months, someone victim of crime | Families had up to 180 days to identify a suitable rental unit and sign a lease. | Females (n=174) | | 1.8 | -0.7 (0.7) | -0.4 (0.9)
| | [underlined: Grp-1] | [underlined: Grp-2] | [underlined: Grp-3] | • Reason(s) in MTO program | Relocators were required to sign leases for 1 year. | Intent-to-treat effects (coefficient estimates) for [underlined: prevalence] of violent crime (percent of teens arrested per quarter during postprogram period):
| [underlined: Age:] | | | | Study subject characteristics | [underlined: Notes if any] | | | [underlined: Control] | [underlined: Exp vs.control] | [underlined: Section-8 vs. control]
| 11 | 19.7% | 15.7% | 21.9% | • Teen | **See Ludwig, Duncan, Hirschfield (2000) for detailed definition of violent crime | [underlined: Risk Group of Interest] | | [underlined: Mean] | [underlined: Coef (SE)] | [underlined: Coef (SE)]
| 12 | 21.4% | 23.4% | 19.8% | • Male | | Total sample (n=336)
| 13 | 19.7% | 22.7% | 24.0% | • Age | | Unadjusted | | 2.7 | -0.8 (0.7) | -1.2 (0.8)
| 14 | 22.0% | 19.4% | 15.6% | • Crime arrests preprogram | | Adjusted | | 2.7 | -1.3 (0.7)* | -1.2 (0.8)
| 15 | 17.3% | 18.8% | 18.8% | [underlined: Outcome 1: violence] | | Teens with no preprogram arrests (n=256) | | 2.2 | -1.0 (0.7) | -1.4 (0.8)*
| [underlined: Gender:] | | | | [underlined: Measures:] Over an average of 3.7 years post-program | | Males (n=162) | | 3.8 | -2.1 (1.2)* | -1.3 (1.0)
| Male | 43.8% | 52.0% | 45.8% | • Incidence: Regression-adjusted violent-crime arrest rates per quarter per 100 teens | | Females (n=174) | | 1.8 | -0.7 (0.7)* | -0.4 (0.9)
| [underlined: Race:] | | | | • Prevalence: Regression-adjusted proportion of teens arrested per quarter during the postprogram period | | The experimental and section-8 only groups experience a reduction in violent-crime arrests relative to controls, starting 4 to 6 quarters after randomization
| Af-Am | 96.9% | 96.8% | 98.4 | [underlined: Definition:] Violent crime included assault, robbery, attempted murder, etc.** | | III. [underlined: EFFECTS OF TREATMENT-ON-THE-TREATED (TOT) ON THE PREVALENCE AND INCIDENCE OF VIOLENT-CRIME ARRESTS (*p<0.1 **p<0.05)]
| | | | | [underlined: How measured:] from juvenile arrest records. | | (A)
| | | | | [underlined: Type:] Assault, robbery, attempted murder, other | | [underlined: Experimental Treatment] | | | [underlined: Prevalence(%)] | [underlined: Incidence]
| | | | | [underlined: Circumstance, Proactive/reactive, Weapon used, and Victim-offender relationship:] Unspecified | | Exp families who moved (1) | | | 2.4 | 2.5
| | | | | [underlined: Outcome 2: Effectiveness] Reduction in the number of violent crime arrests from baseline to the postprogram. | | Exp families who did not move (2) | | | 1.5 | 1.6
| | | | | [underlined: Outcome 3: Adverse health] | | Arrest rate for controls who would have moved if assigned to exp gp (3) | | | 5.0 | 5.7
| | | | | Not studied | | Effects of TOT (1) – (3) | | | -2.6 (1.4)* | -3.2 (1.5)**
| | | | | [underlined: Outcome 4: Safety] | | (B)
| | | | | Not studied | | [underlined: Section-8 Only Treatment] | | | [underlined: Prevalence(%)] | Incidence
| | | | | | | Section-8 families who moved (4) | | | 1.9 | 1.9
| | | | | | | Section-8 families who did not move (5) | | | 0.7 | 0.7
| | | | | | | Arrest rate for controls who would have moved if assigned to Section-8 gp (6) | | | 3.9 | 4.3
| | | | | | | Effects of TOT (4) – (6) | | | 2.0 (1.1)* | 2.4 (1.2)**
| | | | | | | The experimental and section-8 only groups experience a reduction in violent-crime arrests relative to controls, starting 4 to 6 quarters after randomization
Record # | Study Quality | Time/Place | Prevention intervention: Definition and characteritic | Findings
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
7158 | [underlined: Study Design] Randomized controlled trial | [underlined: Time (begin, end):] | [underlined: Description of Program] | A twelve-year follow-up study of maltreated and at-risk children who received early therapeutic child care, examining the psychosocial functioning and home environment in early adolescence.
Moore 1998 Child Maltreatment | [underlined: Individual study quality score] | T1- 1980 began enrollment/ | [underlined: Name of program] | [underlined: 1. Violent Crime from Juvenile Court files]
| • retention rate <80% | T4 -1992 follow-up evaluation | Childhaven's therapeutic child-care program (formerly Seattle Day Nursery) | Serious/Violent crime record: #/total (%)
| • no adjustment of confounding factors. | [underlined: Place (city, state):] Seattle, Washington | [underlined: Level:] Secondary | | TX | CX | p
| • no intent-to-treat analysis | [underlined: Study Population]: Abused, neglected, and at risk infants and toddlers (ages 1 month through 5 years of age) | [underlined: Kind of program] | | 1/27 (4%) | 5/21 (24%) | <0.08
| [underlined: Sample size (initial and actual)] | [underlined: Inclusion criteria]: | • Therapeutic child-care program | Serious/violent arrests: M ± SD
| Overall 61- original sample | • Children expected to remain with their families if treatment was provided | • Parent education | | TX | CX | p
| Treatment (TX)=32 | [underlined: Exclusion criteria]: children with | • Support groups | | 0.04±0.20 | 0.3±0.7 | <.05
| Control CX=29 | • severe intellectual impairment | • Counseling | [underlined: 2. Incidence of fighting from school files]
| T4 sample-42 (69%) | • severe developmental disorder | • Linkages to other professional services | | TX | CX | p
| TX=21 | • in immediate life threatening situations | [underlined: Mechanism of delivery] | % | 2/17 (12%) | 4/11 (36%) | <.05
| CX=14 | [underlined: Moderating/mediating factors] | Individualize programs of concrete services—may include individual and family interventions for children and parents. | M±SD | 0.2 ± 0.7 | 0.8 ± 1.4 | ns
| Age: | Non-specified | [underlined: Target population] | 3. The findings for violent behavior were not reported separated, thus could not be abstracted.
| T1- range= 1–24 months | [underlined: Outcome 1: violence] | Abused, neglected, and at risk infants and toddlers 12 years after intervention. Parents and siblings also received intervention. Parent participation is voluntary | Study suggests that early intervention can support an enhanced trajectory of child and family development. TX youths were less prone to violent delinquency, clinical aggression, and anger. CX youth experienced a significant increase in disciplinary actions from middle to late childhood.
| T4- range=12–14 (M=13 (SD=0.8) | Measures/Definition: | [underlined: Setting where intervention took place:] Child care center. | Significant differences between follow up treatment and control groups include:
| TX: 13.0 (0.8) | 1. Violent crimes (assault) from juvenile court and school files | [underlined: Setting where subjects were recruited:] CPS or Child welfare Services Medical and social service network provided referrals of children at risk. | • Tx group held higher proportion of African American youths (also true at enrollment)
| CX: 13.4 (0.8) | 2. Incidence of “Fighting” from school files | [underlined: Person delivering program] | • Higher percentage of treatment children's fathers had an arrest record
| | 3. reported violent behavior, 6 items from the Problem Behavior Scale (PBS). Youths categorized as ‘violent’ if they received a frequency rating of 3 or greater on any of the 3 PBS violence items. | Not described | • No children in follow up control group had been classified as “at risk”
| | [underlined: Circumstance, Proactive/reactive, Weapon used, Victim-offender relationship:] Not reported | [underlined: Time period/duration/frequency] | • Limited statistical power of the study due to small sample sizes
| | [underlined: Outcome 2: Adverse health] | Treatment children remained in the program on average of 23 mnths (SD=11). 62% of TX parents had “major” participation. 25% of TX parents had no participation.
| | [underlined: Outcome 3: Effectiveness]
| | [underlined: Outcome 4: Safety]
| | Not reported.
Record# | Study Quality | | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | | Inclusion/Exclusion Criteria
| | | Outcome Definition
10786 | [underlined: Study Design]: Nonrandomized controlled trial - Comparison of a change of the orientation of a program | | [underlined: Time (begin, end):] April 1987-August 1990 | [underlined: Description of Program] | To compare the behavioral changes that occurred in two treatment groups that were served with two orientations of a multimodal treatment approach in incarcerated male juvenile offenders
Morrissey 1997 J Offender Rehabilitation | [underlined: Individual study quality score] | | Group A: Apr 87 - Mar 88 | A multimodal treatment approach that utilizes a range of behavioral, cognitive-behavioral, and psychological skills training methods. Many aspects of the program were improved from the Group A intervention to Group B intervention. | | Grp A Mean | Grp B Mean | P
| Poor (no concurrent control group, no control of potential confounders) | | Group B: Sep 89 - Aug 90 | [underlined: Name of program:] Not named | Violent incidents | 7.1 | 1.5 | *
| [underlined: Sample size (initial and actual)]: | | [underlined: Place (city, state):] Worcester, MA | [underlined: Level:] Tertiary | Assaults on Residents | 1.8 | 0.0 | *
| Overall: | 77 | [underlined: Study Population]: Incarcerated male juvenile offenders | [underlined: Kind of program] | Assaults on staff | 1.8 | 0.0 | *
| Group A Treated Group: | 36 | [underlined: Inclusion criteria]: Not specified | 1. Behavioral | Restraint of resident | 3.8 | 0.5 | *
| Group B Treated Group: | 41 | [underlined: Exclusion criteria]: Not specified | 2. Cognitive-behavioral | Room time for Violent Behaviors | 72.1 | 0.8 | *
| [underlined: Age, gender & race groups]: | | [underlined: Moderating/mediating factors] | 3. Psychological skills training | *Significant at p=.05
| Average age of participants: | | None addressed | [underlined: Mechanism of delivery]
| 16 years 4 months (age not provided for each group) | | [underlined: Outcome 1: violence] | 1. Staff dealt with aggressive or disruptive behavior using room confinement <2 hrs, behavioral contracts, extension of time in program
| Both groups were 100% male. | | •Measure: incident reports filed by staff and Program Director's monthly reports | 2. Individual and group counseling
| [underlined: Group A:] | | •Definition: violent incidents; assaults on staff, assaults on residents, restraint required due to violent behavior, and room isolation due to violent behavior | [underlined: Target population]
| Black | 41.6% | •Type: assult | Incarcerated male juvenile offenders
| White | 33.4% | •Circumstance;Proactive/reactive; Weapon used: not specified | [underlined: Setting where intervention took place]
| Hispanic | 22.2% | •Victim-offender relationship: Peers and facility staff | Secure treatment unit of juvenile facility
| Cape Verdian | 2.7% | [underlined: Outcome 2: Adverse health] | [underlined: Setting where subjects were recruited]
| [underlined: Group B]: | | Not addressed | Secure treatment unit of juvenile facility
| Black | 26.7% | [underlined: Outcome 3: Effectiveness] | [underlined: Person delivering program]
| White | 51.2% | Decrease in level of violence and incidences of assaultive behavior in Group B | 1. Facility staff delivered behavioral component
| Hispanic | 19.5% | [underlined: Outcome 4: Safety] | 2. Master's level clinicians provided individual and group counseling
| Cape Verdian | 2.4% | Not addressed | [underlined: Time period/duration/frequency:]
| | | | Weekdays from 9am – 2:30pm:
| | | | Group A: between 4/87 - 3/88
| | | | Group B: between 9/89 - 8/90
Record # | Study Quality | Time/Place | Prevention intervention: Definition and Characteritic | Findings
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
692 | [underlined: Study Design]: Nonrandomized control trial | [underlined: Study Period (begin, end):] Between July 1997 and July 1998 | [underlined: Description of Program] | This study assessed the effectiveness of Project Back-on-Track, an after school diversion program that uses a multimodal approach for the treatment of early-career juvenile offenders.
Myers 2000 J Am Acad Child Adolesc Psychiatry | [underlined: Individual study quality score] | [underlined: Place (city, state):] Not specified | [underlined: Name of program] | Number of violent crimes committed at 12-month follow-up
| Poor (comparability of groups not maintained, key confounders were given little or no attention) | [underlined: Study Setting:] Child and adolescent psychiatry outpatient clinic setting | Project Back-on-Track | Crimes | Program (n=30) # | Control (n=30) #
| [underlined: Sample size]: | [underlined: Study Population:] Early career juvenile offenders | [underlined: Level] | Assault/battery | 0 | 4
| Program participatns: 30 | [underlined: Inclusion criteria:] Youths referred for violent offenses and met criteria for conduct disorder | Tertiary | Aggravated assault/battery | 2 | 1
| Control group: 30 | [underlined: Exclusion criteria:] Not specified | [underlined: Kind of program] | Attempted aggravated assault/battery | 0 | 1
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | [underlined: Moderating/mediating factors] | Family therapies, parent groups, educational sessions, community service projects, and empathy-building exercises | p=ns.
| Program Participants | Not specified | [underlined: Mechanism of delivery]
| Age: 9 to 17 years old (M-14.2, SD-1.9) | [underlined: Outcome 1: violence] | Child-specific intervention included: anger management, community service projects, communication skills, self-esteem groups, assertiveness skills training, stress management, diversity awareness, and alcohol/drug education.
| Gender: 63% females | [underlined: Measure:] number of violent crime committed at 12 month follow-up | Parent-specific intervention included: Parenting groups, combined parent-child interventions multifamily groups, family life and stress management skills.
| African-American: 63.3% | [underlined: Definition]: Not specified | [underlined: Target population]
| White: 33.3% | [underlined: Type]: Not specified | Youths referred for violent offenses and met criteria for conduct disorder and their parents
| Hispanic: 3.3% | [underlined: Circumstance]: Not specified | [underlined: Setting where intervention took place]
| Control group | [underlined: Proactive/reactive]: Not specified | Child and adolescent psychiatry outpatient clinic setting
| Mean age: 14.9(SD-1.7) | [underlined: Weapon used]: Not specified | [underlined: Setting where subjects were recruited]
| Gender: matched program participants | [underlined: Victim-offender relationship]: Not specified | Referred by the District State Attorney's Office and the State Department of Children and Families and surrounding area mental health professionals.
| Race: matched program participants | [underlined: Outcome 2: Effectiveness] | [underlined: Person delivering program]
| | Reduction in violent crime | Anger management: social work provider and recreational therapist
| | [underlined: Outcome 3: Adverse health] | Community service projects: Program/family coordinator and recreational therapist
| | Not studied | Communication skills: social work provider, recreational therapist, psychologist, and psychiatrist
| | [underlined: Outcome 4: Safety] | Self-esteem groups: social work provider and recreational therapist
| | Not studied | Assertiveness skills training: social work provider, psychologist, and psychiatrist
| | [underlined: Outcome 3: Effectiveness] | Stress management: recreational therapist
| | Those participating in the treatment program will have a greater reduction in criminal recidivism than those in the control group. The program would be cost-effective by reducing criminal recidivism costs in the treated groups compared with the untreated group. | Diversity awareness: recreational therapist
| | [underlined: Outcome 4: Safety] | Alcohol/drug education: psychiatrist and community drug education provider
| | Not studied | Parenting groups: occupational therapist
| | | Combined parent-child interventions multifamily groups: Social work provider and psychologist
| | | Family life and stress management skills: recreational therapist and occupational therapist
| | | [underlined: Time period/duration frequency]
| | | Youth attended the program 2 hours per day, 4 days a week for 4 weeks. Parents attended the program for 15 hours. 2-hour community service projects over 4 weeks.
Record# | Study Quality | | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author | Group(s) and Sample Size | | Inclusion/Exclusion Criteria
Year, Jnl | | | Outcome Definition
3680 | [underlined: Study Design]: Nonrandomized control trial. Assignment of school to program or control was not random. Assignment of class within the intervention school to one of the two curricula was random. | | [underlined: Time (begin, end):] 1994-1995 | [underlined: Description of Program] | [underlined: Outcome 1 Baseline violence behavior]
O'Donnell 1999 J Adolesc Health | [underlined: Individual study quality score] | | [underlined: Place (city, state):] New York, NY | 2 components: | | Percent reporting behavior
| Fair (Nonrandomized study, unsure of comparability of cohorts) | | [underlined: Study Population]: 7^th^ and 8^th^ grade regular education students from 2 school sites | 1. curriculum | Behavior | Cont | Gp 1 | Gp 2 | Total | p
| [underlined: Sample size (initial and actual)]: | | [underlined: Inclusion criteria]: Completion of both baseline and follow-up surveys | 2. curriculum plus service training | Past 3 months | n=553 | n=189 | n=230 | n=972
| Overall | | [underlined: Exclusion criteria]: Students without written informed parental consent and student consent | [underlined: Name of program] | Threaten to beat | 49.1 | 44.8 | 44.5 | 47.1 | ns
| Baseline: 1055 | | [underlined: Moderating/mediating factors] | Reach for Health Community Youth Service program. | Threaten to cut/stab/shot | 16.3 | 12.7 | 11.7 | 14.5 | ns
| Follow-up: 972 (92%) | | • Gender | [underlined: Level] Primary | In physical fight | 47.2 | 39.2 | 40.8 | 44.1 | ns
| [underlined: Curriculum (Gp1]): 13 classrooms; 189 students | | • Grade | [underlined: Kind of program] | Past year
| [underlined: Curriculum+Service (Gp2)] | | • Ethnicity | • community youth service | Cut/stab someone | 9.5 | 7.7 | 8.6 | 9.0 | ns
| 10 classooms; 230 students | | • Social desirability | • comprehensive risk-reduction curriculum | Shot at someone | 5.4 | 5.5 | 6.3 | 5.6 | ns
| [underlined: Control (Gp3)]: 28 classrooms; 553 students | | [underlined: Outcome 1: violence] | [underlined: Mechanism of delivery] | Violence scale (mean) | 1.90 | 1.81 | 1.85 | 1.87 | ns
| [underlined: Age] (mean): | | Measure/Definition: | School curriculum | [underlined: Outcome 2 Violent Behavior at 6-month follow-up]
| 7^th^ grade | 12.2 | mean of 7 items: | [underlined: Target population] | [underlined: Linear regressions]
| 8^th^ grade | 13.2 | • Threatening others in 3 mos | Inner-city adolescents | (Comparing both Intervention groups to Control group)
| [underlined: Gender]: 445 (45.8%) male | | • Fighting in 3 mos | [underlined: Setting where intervention took place] | | Models w/ or w/o interaction
| [underlined: Race]: n (%) | | • Weapon carrying in 1 yr | Schools & community sites | | No interactions | | With interactions
| Latino/Hisp: | 150 (15.4) | • Weapon use in 1 yr | [underlined: Setting where subjects were recruited] | Factor | Coeff (SD) | p-value | Coeff (SD) | p-value
| NonHisp Black: | 776 (79.8) | [underlined: How measured]: Self-report questionnaire | Urban middle schools | Baseline violence | 0.565 (0.028) | <0.0001 | 0.561 (0.028) | <0.0001
| Other/Missing: | 46 ( 4.7) | [underlined: Type]: Threats, fights, weapon use | [underlined: Person delivering program] | 2 Programs | -0.037 (0.061) | ns | 0.092 (0.083) | ns
| | | [underlined: Other characteristics:] not specified. | Teachers and/or staff | 1 Program | -0.016 (0.068) | ns | -0.011 (0.087) | ns
| | | [underlined: Outcome 2: Effectiveness] | [underlined: Time period/duration/frequency] | Male | 0.186 (0.051) | <0.001 | 0.189 (0.051) | <0.001
| | | Violence risk behavior at 6-month follow-up | • Curriculum: 35 lessons in 4 main units in 6 months | 8^th^ grade | -0.023 (0.050) | ns | 0.045 (0.066) | ns
| | | [underlined: Outcome 3: Adverse Health] | • Community youth service - 3hr/week at community site | Hispanic v Black | -0.055 (0.071) | ns | -0.041 (0.071) | ns
| | | Not studied | | Oth race v Black | 0.044 (0.118) | ns | 0.040 (0.118) | ns
| | | [underlined: Outcome 4: Safety] | | Soc desirability | -0.104 (0.087) | ns | -0.096 (0.086) | ns
| | | Not studied | | Grade x Progr 2 | | | -0.279 (0.121) | <0.05
| | | | | Grade x Progr 1 | | | 0.004 (0.133) | ns
| | | | | Intercept | 0.927 (0.138) | <0.0001 | 0.887 (0.141) | <0.0001
| | | | | [underlined: Models by grade]
| | | | | | 7^th^Grade | | 8^th^Grade
| | | | | Factor | Coeff (SD) | p-value | Coeff (SD) | p-value
| | | | | Baseline violence | 0.564 (0.044) | <0.0001 | 0.557 (0.037) | <0.0001
| | | | | 2 Programs | 0.102 (0.079) | ns | -0.206 (0.096) | <0.05
| | | | | 1 Program | 0.010 (0.083) | ns | -0.036 (0.113) | ns
| | | | | Male | 0.180 (0.067) | <0.01 | 0.211 (0.078) | <0.01
| | | | | Hispanic v Black | -0.121 (0.089) | ns | 0.058 (0.113) | ns
| | | | | Oth race v Black | -0.221 (0.155) | ns | 0.322 (0.179) | <0.10
| | | | | Soc desirability | -0.075 (0.114) | ns | -0.108 (0.130) | ns
| | | | | Intercept | 0.873 (0.186) | <0.0001 | 0.929 (0.200) | <0.0001
Record # | Study Quality | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
739 | [underlined: Study Design]: Randomized Control Trial Eight middle schools (6–8th grades) were divided into matched pairs and then one of each pair was randomly assigned to either intervention or control conditions. | [underlined: Time (begin, end):] Spring 1994-Spring 1996 | [underlined: Description of Program] | Primary objective was to examine intervention effects at 1-year and 2-year follow-up.
Orpinas 2000 Health Education Research | [underlined: Individual study quality score] | [underlined: Place (city, state):] Urban school district in Texas | Multi-component violence-prevention program | Adjusted difference between intervention and control conditions on outcome variables (adjusted for academic performance and race). Negative scores reflect lower scores for controls, indicating that intervention has higher violence scores.
| • Randomization not adequate | [underlined: Inclusion criteria]: School had not participated in any other violence-prevention study. | [underlined: Name of program] | BOYS, 1-YEAR FOLLOWUP (95% CI)
| • Retention rate <80% | [underlined: Exclusion criteria]: Those who did not complete at least one follow-up evaluation. | Students for Peace | Fighting (%): | -1.2 (-8.5, 6.2)
| [underlined: Sample size (initial and actual):] | [underlined: Moderating/mediating factors] | [underlined: Level:] Primary | Fighting injuries (%): | -2.7 (-7.0, 1.5)
| Overall 2,246; | race/ethnicity | [underlined: Kind of program] | Threatened to hurt (%): | -8.8 (-18.9, 1.3)
| Follow-up rate: | academic performance | Social cognitive program designed to influence both environmental and personal factors. | BOYS, 2-YEAR FOLLOWUP (95% CI)
| 69% all 3 evalations | analyses stratified by gender | [underlined: Components]: | Fighting (%): | -6.3 (-14.1, 1.6)
| 75% at least one follow-up eval | [underlined: Outcome 1: violence] | • Curriculum presenting information about violence, | Fighting injuries (%): | -6.7 (-11.3, 2.1)
| Intervention: (Grp 1): 1,020 | [underlined: Measure]: | • Student training on empathy, conflict resolution, and anger management, | Threatened to hurt (%): | -0.3 (-10.9, 10.4)
| Control: (Grp 2): 1,226 | 1. frequency of fights in school | • Parent education | GIRLS, 1-YEAR FOLLOWUP (95% CI)
| [underlined: Age, gender & race groups:] (for the whole sample only) | 2. frequency of injuries due to fights | [underlined: Mechanism of delivery] | Fighting (%): | -2.1 (-8.5, 4.6)
| Age (only grade mentioned) | [underlined: Definition]: CDC and Preventions' Youth Risk Behavior Survey: | • classroom curriculum | Fighting injuries (%): | 0.9 (-3.6, 5.3)
| 2,246 6^th^ graders at baseline | 1. frequency of fights at school ranged from 0 to 10+ in prior year. | • One-on-one ‘Peer Mediation’ and ‘Peers Helping Peers’ program for student training | Threatened to hurt (%): | 1.9 (-5.5, 9.3)
| 2,090 at one-year followup | 2. frequency of injuries due to fighting ranged from 0 to 6+ in prior year. | • Newsletters to parents for parent education. | GIRLS, 2-YEAR FOLLOWUP (95% CI)
| 1,745 at two-year followup | [underlined: None of these are specified below]: Type, Circumstance, Proactive/reactive, Weapon used Victim-offender relationship | [underlined: Target population] | Fighting (%): | 0.1 (-6.9, 7.1)
| [underlined: Gender] | [underlined: Outcome 2: Adverse health] | Middle school students and their parents | Fighting injuries (%): | -0.7 (-5.3, 3.9)
| 1,132 males (50.4%) | Past year frequency of injuries due to fights. | [underlined: Setting where intervention took place:] School classroom and newsletters to home | Threatened to hurt (%): | -0.6 (-7.2, 8.3)
| 1,114 females (49.6%) | [underlined: Outcome 3: Effectiveness] | [underlined: Setting where subjects were recruited:] School classroom | Overall finding: There is a lack of intervention effect.
| [underlined: Race] | aggression and safety | [underlined: Person delivering program] | Theory on which intervention was based: Social Cognitive Theory.
| Hispanic: 1,537 (68.4%) | [underlined: Outcome 4: Safety] | Teachers and trained students.
| African-American: 382 (17.0%) | Past year frequency of injuries due to fights. | [underlined: Time period/duration/frequency]
| Caucasian: 180 (8.0%) | | • Semester curriculum
| Asian: 79 (3.5%) | | • Monthly newsletters to parents
| Native American: 12 (0.5%)
| other/biracial: 56 (2.5%)
Record # | Study Quality | | | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | | | Inclusion/Exclusion Criteria
| | | | Outcome Definition
9 | [underlined: Study Design]: Randomized control trial (School) | | | [underlined: Time (begin, end):] Academic year 1999-2001 | [underlined: Description of Program] | To evaluate the effect of D.A.R.E. curriculum and supplemental components in reducing tobacco, alcohol and marijuana use and violent behavior.
Perry 2003 Arch Pediatr Adolesc Med | [underlined: Individual study quality score] | | | [underlined: Place (city, state):] Minneapolis-St. Paul | [underlined: Name of program] | [underlined: Violent behavior and Intentions: Mean (SE)]
| 1. Fair based on RCT criteria (no masking of treatment allocation or outcome assessment) | | | [underlined: Study Population]: Seventh and eighth grade students in 24 schools (8 each study group) | Drug Abuse Resistance Education (D.A.R.E.) | [underlined: Boys] | Control | DARE | P
| [underlined: Sample size (initial)]: | | | [underlined: Inclusion criteria]: No additional inclusion criteria. | [underlined: Level:] Primary | | (n=1093) | (n=1269)
| Total eligible: | | 6728 | [underlined: Exclusion criteria]: None noted. | [underlined: Kind of program:] | Baseline score | 7.92 (0.17) | 7.67 (0.17) | .15
| Baseline survey: | | 6238 | [underlined: Moderating/mediating factors] | • Behavioral/cognitive | Growth rate | 0.54 (0.09) | 0.57 (0.09) | .41
| DARE only (1a): | | 2226 | Psychosocial constructs related to violence including demographic variables; normative estimates and expectations concerning violence; and outcomes expectations concerning violence | • Vocational/technical skill building | [underlined: Boys] | Control | DARE Plus | P
| DARE Plus (1b): | | 2221 | [underlined: Outcome 1: violence] | • self-efficacy building | | (n=1093) | (n=1381)
| DelayedControl (2): | | 1790 | [underlined: Measure]: Violent behavior and intentions as measured on a 5-items, scale range: 5–23. | [underlined: Mechanism of delivery] | Baseline score | 7.92 (0.17) | 7.82 (0.16) | .35
| Total (completed at least one survey) | | 7353 | [underlined: How measured] self-administered questionnaire (Kelder and Flay, 1995 and 1994) | • Group setting | Growth rate | 0.54 (0.09) | 0.35 (0.08) | .06
| After excluding loss to follow-up | | 7261 | [underlined: Definition, Type, Circumstance], [underlined: Proactive/reactive, Weapon used, Victim-offender relationship:] Not specified | • Peer mediation | [underlined: Boys] | DARE | DARE Plus | P
| Age and ethnicity for total: | | | [underlined: Outcome 2: Adverse health] | • School curriculum | | (n=1269) | (n=1381)
| [underlined: Age]: 7^th^ and 8^th^ graders | | | Not studied. | • Distribution of material | Baseline score | 7.67 (0.17) | 7.82 (0.16) | .26
| [underlined: Gender] | [underlined: Male] | [underlined: Female] | [underlined: Outcome3: Effectiveness] | • Community action | Growth rate | 0.57 (0.09) | 0.35 (0.08) | .04
| All | 51.6% | 48.4% | [underlined: Definition of outcome measure(s):] Difference between increase of score per year (growth rate) for each measure. | [underlined: Target population] | [underlined: Girl] | Control | DARE | P
| Grp 1a | 1,269 | 1,249 | [underlined: Outcome 4: Safety] | • DARE: 7th & 8th graders | | (n=1015) | (n=1249)
| Grp 1b | 1,381 | 1,254 | Not studied | • DARE Plus: 7th & 8th graders and their parents | Baseline score | 6.66 (0.16) | 6.75 (0.15) | .34
| Grp 2 | 1,093 | 1,015 | | [underlined: Setting where intervention took place] | Growth rate | 0.30 (0.07) | 0.26 (0.07) | .34
| [underlined: Ethnicity]: | | | | • DARE: School | [underlined: Girl] | Control | DARE Plus | P
| White: | | 67.3% | | • DARE Plus: School and community | | (n=1015) | (n=1254)
| African American | | 7.5% | | [underlined: Setting where subjects were recruited:] School | Baseline score | 6.66 (0.16) | 6.67 (0.15) | .49
| Asian American | | 12.7% | | [underlined: Person delivering program] | Growth rate | 0.30 (0.07) | 0.23 (0.07) | .24
| Hispanic | | 3.6% | | • DARE: Police officers | [underlined: Girl] | Control | DARE Plus | P
| American Indian | | 4.0% | | • DARE Plus: officers+peer leaders+community organizers | | (n=1249) | (n=1254)
| Mixed/Other | | 4.9% | | [underlined: Time period/duration/frequency] | Baseline score | 6.75 (0.15) | 6.67 (0.15) | .35
| | | | | • DARE: 10 weeks | Growth rate | 0.26 (0.07) | 0.23 (0.07) | .38
| | | | | • DARE Plus: 10 weeks curriculum + 4 week parental involvement program + unspecified time for extracurricular activities and community action teams.
Record # | Study Quality | | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | | Inclusion/Exclusion Criteria
| | | Outcome Definition
3965 | [underlined: Study Design]: Nonrandomized prospective comparative cohort design. | | [underlined: Time (begin, end):] 1985-2000 | [underlined: Description of Program] | To determine long-term effectiveness of a preschool and school-based intervention program on juvenile arrest.
Reynolds 2001 JAMA | [underlined: Individual study quality score] | | [underlined: Place (city, state):] Chicago, IL | Features central to the program: | [underlined: Outcome 2 Juvenile violent arrests: Adjusted mean and differences*]
| Fair (nonranomized study-unsure of comparability of cohorts) | | [underlined: Study Population]: Children who attended early childhood programs in 25 sites in 1985-1986 | • structured set of learning activities | | [underlined: Preschool children]
| [underlined: Sample size (initial & actual)]: | | [underlined: Inclusion criteria]: Still residing in Chicago at age 10 or older | • low children to teacher ratios in preschool and kindergarten | | Group 1 | Group 2
| Overall: | | [underlined: Exclusion criteria]: None | • multifaceted parent program | [underlined: Outcome] | [underlined: n=911] | [underlined: n=493] | [underlined: Difference] | [underlined: p]
| Initial | 1539 | [underlined: Moderating/mediating factors] | • outreach activities | Any arrest (%) | 9.0 | 15.3 | -6.3 | 0.002
| Actual | 1404 (91%) | • Sex | • ongoing staff development | >=2 arrests (%) | 4.7 | 7.6 | -2.9 | 0.008
| Intervention Group (Grp 1): | | • Race/ethnicity | • health and nutrition services | Mean arrests | 0.22 | 0.35 | -0.13 | 0.02
| Initial | 989 | • Risk index | • comprehensive school-age services | | [underlined: School-age children]
| Actual | 911 (92%) | • Earlier/later program participation | [underlined: Name of program] | | Group1 | Group2
| Control Group (Grp 2): | | • Program Site (local influences) | Chicago Child-Parent Center (CPC) Program | [underlined: Outcome] | [underlined: n=118] | [underlined: n=593] | [underlined: Difference] | [underlined: p]
| Initial | 550 | [underlined: Outcome 1: violence] | [underlined: Level:] Primary | Any arrest (%) | 10.8 | 11.8 | -1.0 | 0.58
| Actual | 493 (90%) | [underlined: Measure:] arrests for violent offenses occurring between ages 10 and 18 years: | [underlined: Kind of program] | >=2 arrests (%) | 5.9 | 5.4 | 0.5 | 0.60
| [underlined: Age, gender & race groups]: | | • Any arrest | • Educational component | Mean arrests | 0.28 | 0.25 | 0.03 | 0.64
| Age: | Not specified | • 2 or more arrests | • Family support component | | [underlined: Intervention Group]
| Gender: | Not specified | • Total number of arrests | [underlined: Mechanism of delivery] | | [underlined: Extended Nonext.]
| Race: | Initial sample only | [underlined: Definition]: Formal petitions for youth who are arrested on criminal charges and go before a judge for violent offenses, such as assault or robbery | Multi-components - see features listed above | [underlined: Outcome] | [underlined: n=540] | [underlined: n = 527] | [underlined: Difference] | [underlined: p]
| Black | 1431 (93%) | [underlined: Type]: Assault, robbery | [underlined: Target population] | Any arrest (%) | 9.3 | 12.4 | -3.1 | 0.09
| Hispanic | 108 (7%) | [underlined: Other characteristics:] unspecified | Low-income minority children | >=2 arrests (%) | 4.9 | 6.2 | -1.3 | 0.19
| | | [underlined: Outcome 2: Effectiveness] | [underlined: Setting intervention took place] | Mean arrests | 0.21 | 0.30 | -0.09 | 0.40
| | | See Outcome 1 | Preschools, kindergarten, neighborhood centers | * Adjusted for factors listed under Moderating/mediating factors. The p value is the probability level of the adjusted mean difference based on probit and negative binomial regression analysis transformed to marginal effects. Sample sizes are for juvenile arrests, larger than that for educational attainment and school remedial services.
| | | [underlined: Outcome 3: Adverse Health] | [underlined: Setting where subjects recruited]
| | | Not studied | Poor communities in Chicago
| | | [underlined: Outcome 4: Safety] | [underlined: Person delivering program]
| | | Not studied | Educators
| | | | [underlined: Time period/duration/frequency]
| | | | • Extended: Full-day or part-day during pre-school and kindergarten, with additional services available through 2^nd^ or 3^rd^ grade
| | | | • Nonextended: Participation at CPC's at any level less than extended participants
Record # | Study Quality | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
7615 | [underlined: Study Design]: Cross-sectional study. Secondary data analysis comparing arrest rates before and after the implementation of the law | [underlined: Time (begin, end):] | [underlined: Description of Program] | This study compared arrest numbers for violent crimes among juveniles for two years before and two years after implementation of the Georgia's Juvenile Justice Reform Act (1994)
Risler 1998 Research on Social Work Practice | [underlined: Individual study quality score] | Before period: 1992 to 1993 | Mandates children age 13–17 arrested for murder, voluntary manslaughter, rape, aggravated sexual battery, aggravated child molestation; aggravated sodomy, or firearm robbery be tried as adult | [underlined: Mean Arrest Rates (unit not provided)]
| Poor (confounding factors not accounted) | After period: 1994 to 1995 | [underlined: Name of program] | | After | Before | % | p
| [underlined: Sample size (initial and actual)]: No population sizes provided. | [underlined: Place (city, state):] State of Georgia | Juvenile Justice Reform Act 1994 of Georgia | Aggravated Assault | 1726.5 | 1833 | -6.16 | 0.482
| [underlined: Age, gender & race groups]: No breakdown of population size by age, gender or race subgroups. | [underlined: Inclusion criteria]: not specified | [underlined: Level]: primary | Armed Robbery | 857 | 749 | 14.41 | 0.238
| | [underlined: Exclusion criteria]: not specified | [underlined: Kind of program:] Legislative | Sex Offense | 426.5 | 393.5 | 8.38 | 0.457
| | [underlined: Moderating/mediating factors:] not specified | [underlined: Mechanism of delivery:] Legislative | Rape | 118 | 121.5 | -2.94 | 0.423
| | [underlined: Outcome 1: violence] | [underlined: Target population:] Juvenile population of the state of Georgia | Murder | 83 | 82 | 1.21 | 0973
| | [underlined: Measure/Definition/Type:] Mean arrest rates for aggravated assault, robbery, sex offense, rape, murder. Data were obtained from the Georgia Uniform Crime Reporting Program. | [underlined: Setting where intervention took place] | Total of Violent Index Offenses | 3211 | 3179 | 1.00 | 0.909
| | [underlined: Circumstance, Proactive/reactive, Weapon used, Victim-offender relationship:] Not specified | State of Georgia | Mean Arrest Rates for Violent Index Offenses
| | [underlined: Outcome 2: Adverse health] | [underlined: Setting where subjects were recruited] | | After | Before | % | p
| | Not specified | State of Georgia | White | 638 | 556 | 14.5 | 0.240
| | [underlined: Outcome 3: Effectiveness] | [underlined: Person delivering program] | Black | 2556 | 2608 | -1.9 | 0.834
| | A statistically significant decrease in the mean arrest rates for the offenses was considered a measure of deterrence. | Legislature | Other | 18 | 14 | 20.6 | 0.606
| | [underlined: Outcome 4: Safety] | [underlined: Time period/duration/frequency] | The analysis suggests that there were no significant reductions in the mean arrest rates for the offenses specified by the law.
| | Not studied | Legislature throughout the post statute period.
| | | [underlined: Notes if any]
| | | • Data gathered from Uniform Crime Reporting Program (FBI 1993, Georgia Bureau of Investigation 1997).
| | | • This study did not report the size of the study population and did not provide a definition of the arrest rate in terms of per x number of population
Record # | Study Quality | | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | | Inclusion/Exclusion Criteria
| | | Outcome Definition
40 | [underlined: Study Design:] Randomized control trial. | | [underlined: Time (begin, end):] Not specified | [underlined: Description of Program] | To determine whether TPRV results in lower rates of violence recidivism when compared with standard court sentencing options (100 hours of community service) for first-time violent offenders
Scott 2002 J Trauma | [underlined: Individual study quality score] | | [underlined: Place (city, state):] Jacksonville, FL | [underlined: Name of program] | [underlined: Violence Recidivism Rate]
| • validity of outcome not addressed | | [underlined: Study Population:] First-time juvenile male offenders of a violent crime | Turning Point: Rethinking Violence (TPRV) | Intervention | Control | p-value
| [underlined: Sample size (initial and actual):] | | [underlined: Inclusion criteria:] First time offender of a violent crime, male ages 13–18 years, residing in Jacksonville area, and screened for “psychological appropriateness” for program | [underlined: Level] | 0.05 | 0.33 | ≤.05
| Total: | 76 | [underlined: Exclusion criteria:] Not specified | Tertiary | Note: The lower recidivism in the study group occurred with a shorter overall time investment (14 core contact hours vs 100 community services hours.
| Intervention Group: | 38 | [underlined: Moderating/mediating factors] | [underlined: Kind of program]
| Control Group: | 38 | None specified | Component 1: Trauma experience
| [underlined: Age, gender & race groups:] Mean age | | [underlined: Outcome 1: violence] | Component 2: Victim Impact panel
| Intervention group: | 15.32 | [underlined: Measure:] Violence recidivism | Component 3: Group Process
| Control group: | 16.08 | [underlined: Definition:] Conviction for violent offense within one year after the first violent conviction and completion of court sanctions | Component 4: Community Networking
| Males: | 76 (100%) | [underlined: Type:] Not specified | [underlined: Mechanism of delivery]
| Race | | [underlined: Circumstance:] Not specified | Group setting
| [underlined: Intervention group] | [underlined: #] | [underlined: Proactive/reactive:] Not specified | [underlined: Target population]
| African-american: | 24 | [underlined: Weapon used:] Not specified | First-time juvenile male offenders of a violent crime and their parents
| Caucasian: | 13 | [underlined: Victim-offender relationship:] Not specified | [underlined: Setting where intervention took place]
| Other: | 1 | [underlined: Outcome 2: Adverse health] | Shands Jacksonville Medical Center
| [underlined: Control group] | | None specified | [underlined: Setting where subjects were recruited]
| African-american: | 24 | [underlined: Outcome 3: Effectiveness] | Intervention group: referred by juvenile judge
| Caucasian: | 13 | Lower recidivism rate and shorter overall time investment. | Control group: random selection from juvenile records
| Other: | 1 | [underlined: Outcome 4: Safety] | [underlined: Person delivering program]
| | | Definition of outcome measure(s) Not specified. | Component 1: health care providers
| | | | Component 2: Victims' families
| | | | Components 3 & 4: Not specified
| | | | [underlined: Time period/duration/frequency]
| | | | 6 weeks, 14 hours of face-to-face contact hours
| | | | [underlined: Notes:] Intervention group received the experimental program. Control group received standard court sentencing options, usually 100 hours of community service.
Record # | Study Quality | | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | | Inclusion/Exclusion Criteria
| | | Outcome Definition
4315 | [underlined: Study Design:] | | [underlined: Time (begin, end):]Not specified (1-year duration) | [underlined: Description of Program] | To test the impact of a school-based substance-abuse-prevention program on risk for violence
Simon 2002 Am J Health Behav | Randomized control trial (group); 29 school districts were recruited with a procedure approximating random selection. 21 continuation high schools were selected based on school size. Schools were blocked by characteristics such as substance-abuse prevalence, ethnicity, size, and test scores and were randomly assigned by block to 1 of 3 experimental conditions: | | [underlined: Place (city, state):]CA (southern) | The program was designed specifically to meet the needs of youth in continuation high schools, the alternative school system in CA. | [underlined: Outcome 1 Perpetration of violence at 1 year follow-up]
| Grp 1: TND curricula | | [underlined: Study Population]: Students from 21 continuation high schools from 5 counties | [underlined: Name of program] | [underlined: % reporting any perpetration]
| Grp 2: TND plus supplemental program | | [underlined: Inclusion criteria]: None | Project Towards No Drug Abuse (TND) | | TND | Control
| Grp 3: Control | | [underlined: Exclusion criteria]: Students in independent study, completing final credits, or not taking the core classes within which TND was delivered | [underlined: Level:]Secondary | Males | 60.1 | 67.9
| [underlined: Individual study quality score] | | [underlined: Moderating/mediating factors] | [underlined: Kind of program:]Behavioral, cognitive Motivation, skills, decision-making | Females | 55.9 | 54.8
| • attrition rate > 20% | | • Gender | [underlined: Mechanism of delivery] | [underlined: Outcome 2 TND Association with Violence]
| • validity of instruments not reported | | • Race/ethnicity | School curriculum | Multivariate logistic regressions by sex: (adjusted for baseline violence, survey procedure, and race/ethnicity)
| • no intent-to-treat analysis | | • Survey procedure | [underlined: Target population] | [underlined: Adjusted Odds Ratios for Perpetration of Violence]
| [underlined: Sample size (initial and actual)]: | | • Baseline violence | Youth in continuation high schools | | [underlined: aOR (95% CI)]
| Overall | | [underlined: Outcome 1: violence] | [underlined: Setting where intervention took place] | | Control | TND
| Baseline | 1587 | [underlined: Measure]: Perpetration of violence | Continuation high schools | Males | 1.23 (0.79–1.90) | 1.00
| 1-yr follow-up | 1074 | [underlined: Definition]: Number of times in the past 12 months, | [underlined: Setting where subjects were recruited] | Females | 0.90 (0.56–1.45) | 1.00
| Complete data | 850 | • slapped, punched, kicked, or beat up someone | Continuation high schools | Note: The 2 intervention conditions did not differ on follow-up reports of perpetration (p=0.65). As a results, the 2 intervention conditions were combined in analysis.
| (Size by group: not specified) | | • used a weapon to threaten a person | [underlined: Person delivering program]
| [underlined: Age, gender & race groups]: | | • used a weapon to injure someone | Trained health educator
| Age: 16.8 mean; 14–19 range | | [underlined: How measured]: In-person or telephone survey; 6-response choices per item | [underlined: Time period/duration/frequency]
| Gender: | 55% male | [underlined: Other characteristics]: not specified | Nine 40-minute lessons or complete classroom periods over a period of 3 weeks
| Race: | | [underlined: Outcome 2: Effectiveness]
| African American | 9% | • TND exposure association with risk for violence
| Asian American | 4% | [underlined: Outcome 3: Adverse Health]
| Latino | 49% | Not studied
| Native American | 3% | [underlined: Outcome 4: Safety]
| White | 34% | Not studied
| Other | 1%
Record # | Study Quality | Time/Place | Prevention intervention: Definition and characteritic | Findings
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
7973 | [underlined: Study Design:] Single group time series study | [underlined: Time (begin, end):] | [underlined: Description of Program] | To report the effectiveness of an outpatient behavioral management program in reducing aggressive behaviors among adolescents diagnosed as oppositional-defiant with aggressive behavior.
Stein 1999 Aggressive Behavior | [underlined: Individual study quality score] | Exact date unspecified | PRETHERAPY ASSESSMENT | Weekly mean rate of aggressive acts for all 16 participants and program phase:
| Poor (no control group) | Total study period = 5 years (Each subject studied for 1 year) | Baseline Phase: 4 weeks | BASELINE
| [underlined: Sample size (initial and actual):] n=16 | [underlined: Place (city, state):] Farmville, Virginia | Cognitive/Rest Phase: 8 weeks | Week | 1 | 2 | 3 | 4
| [underlined: Age, gender & race groups:] | [underlined: Study Population:] Adolescents referred for outpatient treatment to a private psychological clinic for behavioral patterns diagnosed as oppositional-defiant disorder with aggression | Cognitive/Rest+Response Cost Phase: 8 wkss | Mean rate | 4 | 3 | 2 | 4
| [underlined: Age:] Range 13–17 years | [underlined: Inclusion criteria:] See above | POSTTHERAPY ASSESSMENT | COGNITIVE/REST
| [underlined: Gender:] | [underlined: Exclusion criteria:] Unspecified | REST + Response Cost Phase: After aggression stopped, programs remained in effect at home | Week | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12
| Male: 13 (81%) | [underlined: Moderating/mediating factors] | FOLLOW-UP PHASE: One year later, parents recorded observations for two weeks | Mean rate | 3 | 4 | 3 | 3 | 4 | 3 | 5 | 3
| Female: 3 (19%) | Unspecified | [underlined: Name of program] | COGNITIVE/REST + RESPONSE COST
| [underlined: Race:] Unspecified | [underlined: Outcome 1: violence] | Three programs combined: | Week | 13 | 14 | 15 | 16 | 17 | 18 | 19 | 20
| | [underlined: Measure:] Aggressive behavior | 1) Cognitive therapy | Mean rate | 2 | 2 | 3 | 1 | 1 | 0 | 0 | 0
| | [underlined: Definition:] Actual violent contact with either hands or feet or using or throwing an object at parents, siblings, or any other person in the home or any other setting. | 2) REST (Real Economy System for Teens) program | REST + RESPONSE COST
| | [underlined: Type:] Physical aggression | 3) Response cost program | Week | 21 | 22 | 23 | 24
| | [underlined: Circumstance:] Unspecified | [underlined: Level:] Tertiary | Mean rate | 0 | 0 | 0 | 0
| | [underlined: Proactive/reactive:] Unspecified | [underlined: Kind of program :] Cognitive/behavioral | FOLLOW-UP
| | [underlined: Weapon used:] Hands, feet, other object | [underlined: Mechanism of delivery] | FU # | 1 | 2
| | [underlined: Victim-offender relationship:] family or other | • One-on-one (cognitive therapy) | Mean rate | 0 | 0
| | [underlined: Outcome 2:Adverse health &safety] | • Other two programs delivered at home by parents (parents underwent training) | [underlined: Notes:]
| | Not studied | [underlined: Target population] | • Range of aggressive acts was highly variable during baseline
| | [underlined: Outcome 3: Effectiveness] | Adolescents with oppositional-defiant disorder and aggressive behaviors | • Variability increased during the Cognitive/REST phase, even though averages remained fairly consistent
| | A decrease in the number of aggressive acts performed by subjects during intervention and one-year after intervention completed | [underlined: Setting where intervention took place] | • Aggression declined to “0” during the cognitive/REST + Response Cost Phase (by week 18). All participants were at “0” by week 19.
| | [underlined: Outcome 4: Safety] | Outpatient psychological health clinic, Home
| | Not studied | [underlined: Setting where subjects were recruited]
| | | Outpatient psychological health clinic (3 referred by police or courts, 13 initiated by parental concern/frustration)
| | | [underlined: Person delivering program]
| | | Therapist, Parents
| | | [underlined: Time period/duration]
| | | • Duration of intervention ≈ 25 weeks
| | | • Follow up = 2 weeks (1 year after completion of intervention)
| | | • Total time period ≈ 1 year , 27 weeks
Record # | Study Quality | Time/Place | Prevention Intervention: Definition and Characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | Inclusion/Exclusion Criteria
| | Outcome Definition
4962 | [underlined: Study Design]: Partially randomized controlled study with a cross-over design, profiled matched, and wait-list controlled | [underlined: Time (begin, end):] Not specified | [underlined: Description of Program] | The purpose of this study was to assess whether a martial arts course reduce the rate of violence among middle school students.
Zivin 2001 Adolescence | [underlined: Individual study quality score] | [underlined: Place (city, state):] Not specified. School was located in a working-class and welfare-receiving neighborhood that had the 3rd highest juvenile arrate in the city. | A traditional martial arts training program that is aimed at developing a respectful attitude, physical skill, spiritual clarity, and an understanding of the body and the physics of action. | Comparison of Groups A and B post course
[Prior related studies: Delva-Tauiliili, 1995; Edelman, 1994; Glanz 1994; Smith et al 1999] | Poor (Lost to follow-up >20%; potential confounders not controlled for). | [underlined: Study Population:] 6th and 7th grade students in an urban public middle school with 870 students. | [underlined: Name of program] | | Group A | Group B
| [underlined: Sample size (initial and actual)]: Overall: 60 | [underlined: Inclusion criteria]: Administrative staff and/or teachers selected 64 boys who they deemed to be at high risk for violence and delinquency | Koga Ha Kosho Shorei Ryu Kempo | | (n=31) | (n=17)
| [underlined: Group A]: Treatment group | [underlined: Exclusion criteria]: Not specified | [underlined: Level:] Primary | | M(SD) | M(SD)
| N=32 in semester 1; | [underlined: Moderating/mediating factors] | [underlined: Kind of program:] traditional martial arts training | Violent score | 3.20(1.46) | 3.34(1.05)
| N=19 crossed-over to no treatment in semester 2. | Not specified | [underlined: Mechanism of delivery] | Not statistically significant at p=0.05.
| [underlined: Group B]: Wait-list control gp | [underlined: Outcome 1: violence] | Large class room setting with moveable seats
| N=28 in semester 1; | [underlined: Measure]: Violence was based on 9 items selected from the Sutter-Eyberg Student Behavior Inventory at 4 month follow-up measured on a 7-point Likert scale | [underlined: Target population]
| N=17 crossed-over to treatment group in semester 2. | [underlined: Definition]: Not specified | 6th and 7th grade students
| [underlined: Age, gender & race groups]: | [underlined: Outcome 2: Adverse health] | [underlined: Setting where intervention took place]
| [underlined: Age]: | Not specified | School
| 22 6^th^ graders (M=12.1, SD=.46); | [underlined: Outcome 3: Effectiveness] | [underlined: Setting where subjects were recruited]
| 28 7^th^ graders (M=13.11, SD=.43); | Not specified | School
| 10 8^th^ graders (M=14.3, SD=.52) | [underlined: Outcome 4: Safety] | [underlined: Person delivering program]
| [underlined: Gender]: 100% males | Not specified | Martial arts master and his adult assistant
| [underlined: Race]: Not specified | | [underlined: Time period/duration/frequency]
| | | Three times/week for 30 sessions, 45 minutes each