# Appendix B: Screening and Study Quality Review Forms and Evidence Tables 1 and 2

Appendix B-1 Form 1: Title and Abstract Screening Form

Appendix B-2 Form 2: Secondary Screening Form for Full-length articles

Appendix B-3 Form 3: Study Quality Review Form

## Appendix B-4

Evidence Table 1. Risk Factors Contributing to Violent Behavior and Adverse Health Outcome

Record # | Study Quality | Study Characteristic | Outcome (Violence) Definition and characterization | Findings
# Author Year, Jnl | Group Demographics | Risk Factors Studied | | Implications
| Sample Size | Inclusion/Exclusion Criteria
| [underlined: Study Design]: | [underlined: Study Period (begin, end):] | [underlined: Outcome (violence):] | [underlined: Violence Outcome]
| [underlined: Study Quality Score:] | [underlined: Place (city, state):] | [underlined: Outcome measure] | [Give a brief statement of the primary objective of the study, then concisely and systematically record the findings.]
| Element score: | [underlined: Study Setting:] | [underlined: Definition] | [underlined: SAMPLE FORMAT]
| Domain score: | [underlined: Study Population:] | [underlined: Instrument used to measure outcome] | | [underlined: # (%) with violence outcome]
| [underlined: Sample size:] | [underlined: Inclusion criteria:] | [underlined: Type] | [underlined: Risk Factor] | [underlined: Grp 1] | [underlined: Grp 2] | [underlined: Effect size]
| [underlined: Description of cohort(s) by age, gender, & race/ethnicity] | [underlined: Exclusion criteria:] | [underlined: Circumstance/Situational Context] | [underlined: Associated Adverse Health Outcome]
| Age | [underlined: Main independent factor(s):] | [underlined: Proactive/Reactive] | [underlined: SAMPLE FORMAT]
| Gender | [underlined: Instrument used to measure factors:] | [underlined: Weapon used] | | | [underlined: # (%) with outcome]
| Race | [underlined: Covariates] | [underlined: Victim-offender relationship] | [underlined: Risk Factor] | [underlined: Grp 1] | [underlined: Grp 2] | [underlined: Effect size]
| | | [underlined: Adverse Health Outcome]:
| | | [underlined: Type]
| | | [underlined: Definition]
| | | [underlined: Are mechanisms of violence theorized?]
| | | Yes
| | | No
| | | [underlined: If yes, state the theory:]

## Appendix B-5

Evidence Table 2. Effectiveness of Prevention Interventions to Violent Behavior and Adverse Health Outcome

Record # | Study Quality | | | | Time/Place | Prevention intervention: Definition and characteristic | Findings
Author Year, Jnl | Group(s) and Sample Size | | | | Inclusion/Exclusion Criteria
| | | | | Outcome Definition
| [underlined: Study Design]: | | | | [underlined: Time (begin, end):] | [underlined: Description of Program] | [Give a brief statement of the primary objective of the study, then concisely and systematically record relevant findings.]
| [underlined: Individual study quality score] | | | | [underlined: Place (city, state):] | [underlined: Name of program] | [underlined: SAMPLE FORMAT]
| [underlined: Sample size (initial and actual)]: | | | | [underlined: Study Population]: | [underlined: Level] | | [underlined: # (%) with outcome]
| Overall | | | | [underlined: Inclusion criteria]: | [underlined: Kind of program] | [underlined: Outcome 1] | [underlined: Treated] | [underlined: Control]
| Intervention Group (Grp 1) | | | | [underlined: Exclusion criteria]: | [underlined: Mechanism of delivery] | [underlined: Outcome 2] | [underlined: Treated] | [underlined: Control]
| Control Group (Grp 2) | | | | [underlined: Moderating/mediating factors] | [underlined: Target population] | [underlined: Outcome 3] | [underlined: Treated] | [underlined: Control]
| [underlined: Age, gender & race groups]: | | | | [underlined: Outcome 1: violence] | [underlined: Setting where intervention took place] | [underlined: Outcome 4] | [underlined: Treated] | [underlined: Control]
| | All | Grp1 | Grp2 | Measure | [underlined: Setting where subjects were recruited]
| Age | | | | Definition | [underlined: Person delivering program]
| Gender | | | | How measured | [underlined: Time period/duration/frequency]
| Race | | | | Type | [underlined: Notes if any]
| | | | | Circumstance
| | | | | Proactive/reactive
| | | | | Weapon used
| | | | | Victim-offender relationship
| | | | | [underlined: Outcome 2: Effectiveness]
| | | | | Definition of outcome measure(s)
| | | | | [underlined: Outcome 3: Adverse Health]
| | | | | Definition of outcome measure(s)
| | | | | [underlined: Outcome 4: Safety]
| | | | | Definition of outcome measure(s)