# Appendix A: DIALOG Strategies

## Appendix A-1 DIALOG Strategy for MEDLINE #1

1. EX SD054
2. S DANGEROUS BEHAVIOR/DE OR VIOLENCE/DE OR DOMESTIC VIOLENCE!/DE OR TORTURE/DE OR RAPE/DE OR HOMICIDE!/DE
3. S DC=C21.866? AND CRIME!/DE [wounds and injuries]
4. S VIOLENCE/TI OR VIOLENT/TI OR RAPE/TI OR RAPED/TI OR RAPING/TI OR VIOLENT(W)CRIME? OR DANGEROUS(W)BEHAVIOR?
5. S CHILD/DE, TI OR CHILD, PRESCHOOL/DE OR CHILDREN/TI OR ADOLESCEN?/DE,TI OR YOUTH/TI OR TEEN/TI OR TEENS/TI OR TEENAGER?/TI
6. S YOUTH(W)VIOLENCE OR ADOLESCEN?(W)VIOLENCE OR TEEN(W)VIOLENCE OR TEENAGER?(W)VIOLENCE OR CHILD(W)VIOLENCE OR STUDENT(W)VIOLENCE OR SCHOOL(W)VIOLENCE
7. S AFRICA!/DE OR ANTARCTIC REGIONS/DE OR ARCTIC REGIONS/DE OR ASIA!/DE OR ATLANTIC ISLANDS!/DE OR AUSTRALIA!/DE
8. S EUROPE!/DE OR INDIAN OCEAN ISLANDS!/DE OR PACIFIC ISLANDS!/DE OR USSR!/DE OR CARIBBEAN REGION!/DE OR CENTRAL AMERICA!/DE OR LATIN AMERICA/DE
9. S SOUTH AMERICA!/DE OR CANADA!/DE OR MEXICO/DE OR GREENLAND/DE OR LONDON/DE OR PARIS/DE OR BERLIN/DE OR ROME/DE OR TOKYO/DE OR MOSCOW/DE
10. S PUERTO RICO/DE OR UNITED STATES!/DE
11. S PRACTICE GUIDELINES/DE OR GUIDELINES/DE OR DT=PRACTICE GUIDELINE OR DT=GUIDELINE OR DT=LETTER OR DT=EDITORIAL OR DT=NEWS
12. C 2 OR 3 OR 4
13. C 12 AND 5
14. C 13 OR 6
15. C 7 OR 8 OR 9
16. C 14 NOT 15
17. C 14 AND 10
18. C 16 OR 17
19. C 18 NOT 11
20. c 19 AND 1
21. S WAR!/DE OR PRISONS!/DE OR PRISONERS/DE
22. C 20 NOT 21
23. S22/HUMAN
24. S S23/ENG

## DIALOG Systematic Reviews, etc., Search Strategy for MEDLINE #1A

EXS SD054

1. S META(W)ANALYSIS OR METAANALY? OR EVIDENCE(W)BASED
2. S RANDOMI?ED(N3)(TRIAL?? OR CONTROLLED OR STUDY OR STUDIES OR DOUBLE)
3. S (CONTROLLED OR INTERVENTIONAL OR DRUG OR THERAPEUTIC OR CLINICAL OR PLACEBO)(W3)TRIAL??
4. S BLIND?(W)(TRIAL?? OR STUDY OR STUDIES)
5. S DOUBLE(W)BLIND? AND (TRIAL?? OR STUDY OR STUDIES)
6. S SINGLE(W)BLIND? AND (TRIAL?? OR STUDY OR STUDIES)
7. S (SINGLE?? OR DOUBLE?? OR TRIPLE?? OR TREBLE?)/TI,AB,DE,ID AND (BLIND?? OR MASK?)/TI,AB,DE,ID
8. S CASE(W)CONTROL?(W)(STUDY OR STUDIES)
9. S COHORT(N3)(STUDY OR STUDIES OR STUDIED)
10. S RCT/TI,AB AND TRIAL??/TI,AB,DE
11. S RCTS(N4)(ANALYSIS OR ANALYZ? OR REVIEW? OR EXAMIN? OR EVALUAT?)
12. S TRIAL??(N4)(ANALYSIS OR ANALYZ? OR REVIEW? OR EXAMIN? OR EVALUAT?)
13. S STUDIES(N4)(ANALYSIS OR ANALYZ? OR REVIEW? OR EXAMIN? OR EVALUAT?)
14. S MEDLINE(N4)(ANALYSIS OR ANALYZ? OR REVIEW? OR EXAMIN? OR EVALUAT?)
15. S LITERATURE(N4)(ANALYSIS OR ANALYZ? OR REVIEW? OR EXAMIN? OR EVALUAT?)
16. S CRITICAL?(N4)(ANALYSIS OR ANALYZ? OR REVIEW? OR EXAMIN? OR EVALUAT?)
17. S EVIDENCE(N4)(ANALYSIS OR ANALYZ? OR REVIEW? OR EXAMIN? OR EVALUAT?)
18. S SYSTEMATIC?(N2)(REVIEW? OR OVERVIEW?? OR SURVEY OR SURVEYS OR STUDY OR STUDIES OR LITERATURE)
19. S (COCHRANE??(W)(DATABASE OR STUDY OR STUDIES OR REVIEW??))/TI,AB,DE
20. S QUANTITATIV?(W2)REVIEW(W5)EVIDENCE
21. S CONSENSUS(W)DEVELOPMENT OR PRACTICE(W)GUIDELINE? OR REVIEW??/TI,DE,ID
22. C 1 OR 2 OR 3 OR 4 OR 5 OR 6 OR 7 OR 8 OR 9 OR 10 OR 11 OR 12 OR 13 OR 14 OR 15 OR 16 OR 17 OR 18 OR 19 OR 20 OR 21

## Appendix A-2 DIALOG Strategy for MEDLINE #2

1. S CHILD/DE,TI OR CHILD, PRESCHOOL/DE OR CHILDREN/TI OR ADOLESCEN?/DE,TI OR TEEN/TI OR TEENS/TI OR TEENAGER?/TI
2. S DANGEROUS BEHAVIOR/DE OR VIOLENCE/DE OR TORTURE/DE OR RAPE/DE OR HOMICIDE!/DE OR DOMESTIC VIOLENCE/DE
3. S DC=C21.866? AND CRIME!/DE [WOUNDS AND INJURIES]
4. S (DATE OR DATING OR COURTSHIP OR PARTNER OR SPOUSE OR SPOUSAL)(N3)VIOLENCE OR DATE(W)RAPE
5. S PHYSICAL?(W)(VIOLENCE OR ASSAULT? OR ATTACK?? OR AGGRESSION OR AGGRESSIVE)
6. S (GANG OR GANGS OR GUN OR GUNS OR FIREARM?? OR WEAPON?)(N3)VIOLENCE
7. S (GANG OR GANGS OR GUN OR GUNS OR FIREARM?? OR WEAPON?)(N3)VIOLENT
8. S (SCHOOL? OR CLASSROOM?? OR STUDENT?? OR COLLEGE?? OR UNIVERSITY OR UNIVERSITIES OR INTERPERSONAL)(N3)VIOLENCE
9. S (SCHOOL? OR CLASSROOM?? OR STUDENT?? OR COLLEGE?? OR UNIVERSITY OR UNIVERSITIES OR INTERPERSONAL)(N3)VIOLENT
10. S (YOUTH OR YOUTHS OR ADOLESCEN? OR TEEN OR TEENS OR TEENAGER? OR CHILD OR CHILDREN OR JUVENILE??)(N3)VIOLENCE
11. S (YOUTH OR YOUTHS OR ADOLESCEN? OR TEEN OR TEENS OR TEENAGER? OR CHILD OR CHILDREN OR JUVENILE??)(N3)VIOLENT
12. S VIOLENT(W)(CRIME OR CRIMES OR CRIMINAL? OR DEATH OR DEATHS OR INTERACTION?) OR ARMED(W)ROBBER? OR ANIMAL??(N2)CRUEL?
13. S DRUG(W)RELATED(W)VIOLENCE OR VIOLENCE(W)RELATED OR SADISM OR SADOMASOCHIS? OR SADISTIC
14. S (DESTRUCTIVE OR PHYSICAL OR ABUSIVE OR ATTACK? OR CRUEL OR VIOLENT)(N3)BEHAVIOR??
15. C 2 OR 3 OR 4 OR 5 OR 6 OR 7 OR 8 OR 9 OR 10 OR 11 OR 12 OR 13 OR 14
16. S CHILD ABUSE/DE OR CHILD ABUSE, SEXUAL/DE OR ELDER ABUSE/DE OR SPOUSE ABUSE/DE OR BATTERED WOMEN/DE OR BATTERED CHILD SYNDROME/DE
17. S SEX OFFENSES/DE OR INCEST/DE OR AGGRESSION/DE OR SUBSTANCE-RELATED DISORDERS!/DE OR MUNCHAUSEN SYNDROME BY PROXY/DE OR CIVIL DISORDERS!/DE
18. S KNIFE OR KNIVES OR KNIFING OR STAB OR STABBING OR STABBED OR TORTURE OR TORTURING OR TORTURED
19. S GUNSHOT? OR GUN OR GUNS OR RIFLE OR RIFLES OR FIREARM? OR WEAPON? OR SHOOTING?
20. S MURDER? OR HOMICID? OR FEMICID? OR FILICID? OR MUTILATION?? OR MUTILATE?? OR RAPE OR RAPED OR RAPING OR RAPES OR RAPIST?
21. S INJUR? OR ASSAULT? OR BATTER OR BATTERY OR BATTERING OR BATTERED OR ARSON OR FIRE(N2)(SET OR SETTING) OR FIRESETT?
22. S BULLY OR BULLIES OR BULLIED OR BULLYING OR BRUTAL? OR BLUDGEON? OR VIOLENT OR VIOLENCE OR BURN OR BURNS OR BURNING OR STALKING OR STALKER?
23. C 18 OR 19 OR 20 OR 21 OR 22
24. C 16 OR 17
25. C 23 AND 24
26. C (1 AND 15) OR (1 AND 25)
27. S AFRICA!/DE OR ANTARCTIC REGIONS/DE OR ARCTIC REGIONS/DE OR ASIA!/DE OR ATLANTIC ISLANDS!/DE OR AUSTRALIA!/DE
28. S EUROPE!/DE OR INDIAN OCEAN ISLANDS!/DE OR PACIFIC ISLANDS!/DE OR USSR!/DE OR CARIBBEAN REGION!/DE OR CENTRAL AMERICA!/DE OR LATIN AMERICA/DE
29. S SOUTH AMERICA!/DE OR CANADA!/DE OR MEXICO/DE OR GREENLAND/DE OR LONDON/DE OR PARIS/DE OR BERLIN/DE OR ROME/DE OR TOKYO/DE OR MOSCOW/DE
30. S PRACTICE GUIDELINES/DE OR GUIDELINES/DE OR DT=PRACTICE GUIDELINE OR DT=GUIDELINE OR DT=LETTER OR DT=EDITORIAL OR DT=NEWS
31. S DT=INTERVIEW OR DT=LEGAL CASES OR DT=CONSENSUS DEVELOPMENT CONFERENCE OR DT=CONGRESSES OR DT=LECTURES
32. S DT=PATIENT EDUCATION HANDOUT OR DT=LEGISLATION OR DT= REVIEW OR CASE REPORT/DE
33. S WAR!/DE OR PRISONS!/DE OR PRISONERS/DE OR DETENTION(W)CENTER?OR IMPRISONMENT OR INCARCERAT? OR REFORMATORY OR REFORMATORIES OR JAILS
34. S COMBAT OR VIETNAM OR MILITARY OR ARMED(W)(FORCES OR SERVICES)
35. S PROSTITUTION/DE OR SUICIDE!/DE OR SELF-INJURIOUS BEHAVIOR/DE OR MASOCHISM/DE
36. C 27 OR 28 OR 29
37. C 26 NOT 36
38. S PUERTO RICO/DE OR UNITED STATES!/DE
39. C 26 AND 38
40. C 37 OR 39
41. C 30 OR 31 OR 32 OR 33 OR 34 OR 35
42. C 40 NOT 41
43. S S42/HUMAN
44. S S43/ENG

## Appendix A-3 DIALOG Strategy for MEDLINE #3

1. S ADOLESCEN?/DE,TI,AB OR TEEN/TI,AB OR TEENS/TI,AB OR TEENAGER?/TI,AB
2. S JUVENILE/TI,AB OR JUVENILES/TI,AB OR YOUTH/TI,AB OR YOUTHS/TI,AB
3. C 1 OR 2
4. S VIOLENCE OR VIOLENT
5. C 3 AND 4
6. S (SCHOOL? OR CLASSROOM?? OR STUDENT??) AND (VIOLENCE OR VIOLENT)
7. S DANGEROUS BEHAVIOR/DE OR VIOLENCE/DE OR RAPE/DE OR HOMICIDE!/DE OR DOMESTIC VIOLENCE/DE
8. S (DATE OR DATING OR COURTSHIP OR INTERPERSONAL)(N5)VIOLENCE OR DATE(W)RAPE
9. S (DATE OR DATING OR COURTSHIP OR INTERPERSONAL)(N5)VIOLENT
10. S PHYSICAL?(W)(ASSAULT? OR ATTACK?? OR AGGRESSION OR AGGRESSIVE) OR ARMED(W)ROBBER?
11. S KNIFING/TI,AB OR STAB/TI,AB OR STABBING/TI,AB OR STABBED/TI,AB OR GUNSHOT?/TI,AB OR SHOOTING?/TI,AB OR BRUTAL?/TI,AB OR BLUDGEON?/TI,AB
12. S MURDER?/TI,AB OR HOMICID?/TI,AB OR FEMICID?/TI,AB OR FILICID?/TI,AB OR RAPE/TI,AB OR RAPED/TI,AB
13. S RAPING/TI,AB OR RAPES/TI,AB OR RAPIST?/TI,AB OR ASSAULT??/TI,AB OR BULLY/TI,AB OR BULLIES/TI,AB OR BULLIED/TI,AB OR BULLYING/TI,AB
14. C 6 OR 7 OR 8 OR 9 OR 10 OR 11 OR 12 OR 13
15. C 3 AND 14
16. C 5 OR 15
17. S AFRICA!/DE OR ANTARCTIC REGIONS/DE OR ARCTIC REGIONS/DE OR ASIA!/DE OR ATLANTIC ISLANDS!/DE OR AUSTRALIA!/DE
18. S EUROPE!/DE OR INDIAN OCEAN ISLANDS!/DE OR PACIFIC ISLANDS!/DE OR USSR!/DE OR CARIBBEAN REGION!/DE OR CENTRAL AMERICA!/DE OR LATIN AMERICA/DE
19. S SOUTH AMERICA!/DE OR CANADA!/DE OR MEXICO/DE OR GREENLAND/DE OR LONDON/DE OR PARIS/DE OR BERLIN/DE OR ROME/DE OR TOKYO/DE OR MOSCOW/DE
20. S PRACTICE GUIDELINES/DE OR GUIDELINES/DE OR DT=PRACTICE GUIDELINE OR DT=GUIDELINE OR DT=LETTER OR DT=EDITORIAL OR DT=NEWS
21. S DT=INTERVIEW OR DT=LEGAL CASES OR DT=CONSENSUS DEVELOPMENT CONFERENCE? OR DT=CONGRESSES OR DT=LECTURES
22. S DT=PATIENT EDUCATION HANDOUT OR DT=LEGISLATION OR DT= REVIEW OR CASE(W)REPORT?
23. S WAR!/DE OR COMBAT OR VIETNAM OR MILITARY OR ARMED(W)(FORCES OR SERVICES)
24. S PTSD/TI,AB OR POST(W)TRAUMATIC(W)STRESS OR POSTTRAUMATIC(W)STRESS OR STRESS DISORDERS, POST-TRAUMATIC/DE
25. S PROSTITUTION/DE OR SUICIDE!/DE OR SELF-INJURIOUS BEHAVIOR/DE OR MASOCHISM/DE OR BATTERED CHILD SYNDROME/DE OR SHAKEN(W)(BABY OR INFANT)
26. C 17 OR 18 OR 19
27. C 16 NOT 26
28. S PUERTO RICO/DE OR UNITED STATES!/DE
29. C 16 AND 28
30. C 27 OR 29
31. C 20 OR 21 OR 22 OR 23 OR 24 OR 25
32. C 30 NOT 31
33. S S32/HUMAN
34. S S33/ENG

## Appendix A-4 DIALOG Strategy for MEDLINE #4

1. s adolescen?/de,ti,ab or teen/ti,ab or teens/ti,ab or teenager?/ti,ab or juvenile/ti,ab or juveniles/ti,ab or youth/ti,ab or youths/ti,ab
2. s (direct(w)aggression) OR (overt(w)aggression)
3. c 1 AND 2
4. s war!/de OR combat OR vietnam OR military OR armed(W)(forces OR services)
5. s ptsd/ti,ab or post(w)traumatic(w)stress OR posttraumatic(W)stress OR stress disorders, post-traumatic/de
6. s prostitution/de OR suicide!/de OR self-injurious behavior/de OR masochism/de OR battered child syndrome/de OR shaken(W)(baby OR infant)
7. c 4 OR 5 OR 6
8. c 3 NOT 7
9. s s8/HUMAN
10. s s9/ENG
11. t 10/4/1-1000

## Appendix A-5 DIALOG Strategy for PsycINFO #1

1. s child/ti or childhood/ti or ag=100 or children/ti or ag=160 or ag=180 or adolescen?/ti or ag=200 or teen/ti or teens/ti or teenager?/ti
2. s aggressive behavior/de or violence/de or torture/de or rape/de or homicide/de OR family violence/de
3. s crime/de AND (wounds/de OR injuries/de)
4. s (date OR dating OR courtship OR partner OR spouse OR spousal)(n3)violence OR date(w)rape
5. s physical?(w)(violence OR assault? OR attack?? OR aggression OR aggressive)
6. s (gang OR gangs OR gun OR guns OR firearm?? OR weapon?)(n3)violence
7. s (gang OR gangs OR gun OR guns OR firearm?? OR weapon?)(n3)violent
8. S (school? OR classroom?? OR student?? OR college?? OR university OR universities OR interpersonal)(n3)violence
9. S (school? OR classroom?? OR student?? OR college?? OR university OR universities OR interpersonal)(n3)violent
10. s (youth OR youths OR adolescen? OR teen OR teens OR teenager? OR child OR children OR juvenile??)(n3)violence
11. s (youth OR youths OR adolescen? OR teen OR teens OR teenager? OR child OR children OR juvenile??)(n3)violent
12. s violent(w)(crime OR crimes OR criminal? OR death OR deaths OR interaction?) OR armed(w)robber? OR animal??(n2)cruel?
13. s drug(w)related(w)violence OR violence(w)related OR sadism OR sadomasochis? OR sadistic
14. s (destructive OR physical OR abusive OR attack? OR cruel OR violent)(n3)behavior??
15. c 2 OR 3 OR 4 OR 5 OR 6 OR 7 OR 8 OR 9 OR 10 OR 11 OR 12 OR 13 OR 14
16. s child abuse/de OR elder abuse/de OR partner abuse/de OR battered females/de OR battered child syndrome/de OR battered child/de
17. s sex offenses/de OR incest/de OR aggressive behavior/de OR drug abuse/de OR riots/de OR civil(w)disorder?
18. s knife OR knives OR knifing OR stab OR stabbing OR stabbed OR torture OR torturing OR tortured
19. s gunshot? OR gun OR guns OR rifle OR rifles OR firearm? OR weapon? OR shooting?
20. s murder? OR homicid? OR femicid? OR filicid? OR mutilation?? OR mutilate?? OR rape OR raped OR raping OR rapes OR rapist?
21. s injur? OR assault? OR batter OR battery OR battering OR battered OR arson OR fire(n2)(set OR setting) OR firesett?
22. s bully OR bullies OR bullied OR bullying OR brutal? OR bludgeon? OR violent OR violence OR burn OR burns OR burning OR stalking OR stalker?
23. c 18 OR 19 OR 20 OR 21 OR 22
24. c 16 OR 17
25. c 23 AND 24
26. c (1 AND 15) OR (1 AND 25)
27. s war/de OR prisons/de or prisoners/de OR correctional institutions/de OR detention(w)center? OR imprisonment OR incarcerat? OR reformatory OR reformatories OR jails
28. s combat OR Vietnam OR military OR armed(w)(forces OR services)
29. s prostitution/de OR suicide/de OR self destructive behavior/de OR masochism/de
30. c 27 OR 28 OR 29
31. c 26 NOT 30
32. s s31/ENG
33. s dt=journal article
34. c 32 AND 33
35. s s34/1990:2003
36. t 35/7,id,de,la,sh,ag,dt,kc,su,gn/all tag

## Appendix A-6 DIALOG Strategy for PsycINFO #2

1. s ag=adolescent OR adolescen?/ti,ab OR teen/ti,ab OR teens/ti,ab OR teenager?/ti,ab OR juvenile/ti,ab OR juveniles/ti,ab OR youth/ti,ab OR youths/ti,ab
2. s violence OR violent
3. c 1 AND 2
4. s (school? OR classroom?? OR student??) AND (violence OR violent)
5. s violence/de OR rape/de OR homicide/de OR family violence/de
6. s (date OR dating OR courtship OR interpersonal)(n5)(violence OR violent) OR date(W)rape
7. s physical?(W)(assault? OR attack?? OR aggression OR aggressive) OR armed(W)robber?
8. s knifing OR stab OR stabbing OR stabbed OR gunshot? OR shooting? OR brutal? OR bludgeon?
9. s murder? OR homicid? OR femicid? OR filicid? OR rape OR raped OR raping OR rapes OR rapist?
10. s bully OR bullies OR bullied OR bullying OR assault?
11. c 4 OR 5 OR 6 OR 7 OR 8 OR 9 OR 10
12. c 1 AND 11
13. c 3 OR 12
14. s war/de OR combat OR vietnam OR military OR armed(W)(forces OR services)
15. s posttraumatic stress disorder/de OR posttraumatic(W)stress OR post(W)traumatic(W)stress OR ptsd
16. s prostitution/de OR suicide/de OR self destructive behavior/de OR masochism/de OR battered child syndrome/de OR shaken(W)(baby OR infant)
17. c 14 OR 15 OR 16
18. c 13 NOT 17
19. s s18/ENG
20. s dt=journal article
21. c 19 AND 20
22. s s21/1990:2003
23. t 22/7,id,de,la,sh,ag,dt,kc,su,gn/all tag

## Appendix A-7 DIALOG Strategy for PsycINFO #3

1. s ag=adolescence OR adolescen?/ti,ab OR teen/ti,ab OR teens/ti,ab OR teenager?/ti,ab OR juvenile/ti,ab OR juveniles/ti,ab OR youth/ti,ab OR youths/ti,ab
2. s (direct(w)aggression) OR (overt(w)aggression)
3. c 1 AND 2
4. s war/de OR combat OR vietnam OR military OR armed(W)(forces OR services)
5. s posttraumatic stress disorder/de OR posttraumatic(W)stress OR post(W)traumatic(W)stress OR ptsd
6. s prostitution/de OR suicide/de OR self destructive behavior/de OR masochism/de OR battered child syndrome/de OR shaken(W)(baby OR infant)
7. c 4 OR 5 OR 6
8. c 3 NOT 7
9. s s8/ENG
10. s dt=journal article
11. c 9 AND 10
12. s s11/1990:2003
13. t 12/7,id,de,la,sh,ag,dt,kc,su,gn/all tag

## Appendix A-8 DIALOG Strategy for SocAbs #1

1. s children/de,ti OR child/ti or adolescen?/de,ti or teen/ti or teens/ti or teenager?/ti
2. s violence/de or torture/de or rape/de or homicide/de OR family violence/de
3. s crime/de AND injuries/de
4. s (date OR dating OR courtship OR partner OR spouse)(n3)violence OR date(w)rape
5. s physical?(w)(violence OR assault? OR attack?? OR aggression OR aggressive)
6. s (gang OR gangs OR gun OR guns OR firearm?? OR weapon?)(n3)violence
7. s (gang OR gangs OR gun OR guns OR firearm?? OR weapon?)(n3)violent
8. S (school? OR classroom?? OR student?? OR college?? OR university OR universities OR interpersonal)(n3)violence
9. S (school? OR classroom?? OR student?? OR college?? OR university OR universities OR interpersonal)(n3)violent
10. s (youth OR youths OR adolescen? OR teen OR teens OR teenager? OR child OR children OR juvenile??)(n3)violence
11. s (youth OR youths OR adolescen? OR teen OR teens OR teenager? OR child OR children OR juvenile??)(n3)violent
12. s violent(w)(crime OR crimes OR criminal? OR death OR deaths OR interaction?) OR armed(w)robber? OR animal??(n2)cruel?
13. s drug(w)related(w)violence OR violence(w)related OR sadism OR sadomasochis? OR sadistic
14. s (destructive OR physical OR abusive OR attack? OR cruel OR violent)(n3)behavior??
15. c 2 OR 3 OR 4 OR 5 OR 6 OR 7 OR 8 OR 9 OR 10 OR 11 OR 12 OR 13 OR 14
16. s child abuse/de OR child sexual abuse/de OR elder abuse/de OR spouse abuse/de OR battered women/de
17. s sex offenders/de OR incest/de OR aggression/de OR substance abuse/de OR civil disorders/de OR riots/de
18. s knife OR knives OR knifing OR stab OR stabbing OR stabbed OR torture OR torturing OR tortured
19. s gunshot? OR gun OR guns OR rifle OR rifles OR firearm? OR weapon? OR shooting?
20. s murder? OR homicid? OR femicid? OR filicid? OR mutilation?? OR mutilate?? OR rape OR raped OR raping OR rapes OR rapist?
21. s injur? OR assault? OR batter OR battery OR battering OR battered OR arson OR fire(n2)(set OR setting) OR firesett?
22. s bully OR bullies OR bullied OR bullying OR brutal? OR bludgeon? OR violent OR violence OR burn OR burns OR burning OR stalking OR stalker?
23. c 18 OR 19 OR 20 OR 21 OR 22
24. c 16 OR 17
25. c 23 AND 24
26. c (1 AND 15) OR (1 AND 25)
27. s war/de OR vietnam war/de OR prisons/de or prisoners/de OR detention(w)center? OR imprisonment OR incarcerat? OR reformatory OR reformatories OR jails
28. s combat OR Vietnam OR military OR armed(w)(forces OR services)
29. s prostitution/de OR suicide/de OR self destructive behavior/de OR masochism
30. c 27 OR 28 OR 29
31. c 26 NOT 30
32. s s31/ENG
33. s DT=FEATURE ARTICLE
34. c 32 AND 33
35. s s34/1990:2003
36. t 35/7,de,la,dt,gn/all tag

## Appendix A-9 DIALOG Strategy for SocAbs #2

1. s adolescen?/de,ti,ab or teen/ti,ab or teens/ti,ab or teenager?/ti,ab
2. s violence or violent
3. c 1 AND 2
4. s (school? OR classroom?? OR student??) AND (violence or violent)
5. s violence/de or rape/de or homicide/de OR family violence/de
6. s (date OR dating OR courtship OR interpersonal)(n5)(violence OR violent) OR date(W)rape
7. s physical?(W)(assault? OR attack?? OR aggression OR aggressive) OR armed(W)robber?
8. s gunshot? OR shooting? OR knifing OR stab OR stabbing OR stabbed OR brutal? OR bludgeon?
9. s murder? OR homicid? OR femicid? OR filicid? OR rape OR raped OR raping OR rapes OR rapist?
10. s bully OR bullies OR bullied OR bullying OR assault?
11. c 4 OR 5 OR 6 OR 7 OR 8 OR 9 OR 10
12. c 1 AND 11
13. c 3 OR 12
14. s war/de OR combat OR vietnam war/de OR Vietnam OR military OR armed(W)(forces OR services)
15. s posttraumatic stress disorder/de OR posttraumatic(W)stress OR post(w)traumatic(w)stress OR ptsd
16. s prostitution/de OR suicide/de OR self destructive behavior/de OR masochism OR battered(W)child(W)syndrome OR shaken(W)(baby OR infant)
17. c 14 OR 15 OR 16
18. c 13 NOT 17
19. s s18/ENG
20. s DT=FEATURE ARTICLE
21. c 19 AND 20
22. s s21/1990:2003
23. t 22/7,de,la,dt,gn/all tag