# Reference List for Table C-2

Abraham W T. Cardiac resynchronization therapy for heart failure: Biventricular pacing and beyond. Curr Opin Cardiol. 2002;17(4):346-352. [pmid: 12151867].
Auricchio A, Stellbrink C, Sack S, et al. Long-term clinical effect of hemodynamically optimized cardiac resynchronization therapy in patients with heart failure and ventricular conduction delay (PATH CHF Trial). J Am Coll Cardiol. 2002;39(12):2026-2033. [pmid: 12084604].
Comparison of medical therapy, pacing and defibrillation in heart failure (COMPANION Trial). Presented at the 52nd Annual Scientific Conference, American College of Cardiology, Chicago, illinois, USA, March 31st: 2003.
Cazeau S, Ritter P, Lazarus A, et al. Multisite pacing for end-stage heart failure: early experience. PACE. 1996;19:1748-1757. [pmid: 8945034].
Cazeau S, Leclercq C, Lavergne T, et al. Effects of multisite biventricular pacing in patients with heart failure and intraventricular conduction delay. (MUSTIC SR). N Engl J Med. 2001;344(12):873-880. [pmid: 11259720].
Filho M M, Pedrosa A A, Costa R, et al. Biventricular pacing improves clinical behavior and reduces prevalence of ventricular arrhythmia in patients with heart failure. Arq Bras Cardiol. 2002;78(1):110-113. [pmid: 11826352].
Gras D, Leclercq C, Tang A S, et al. Cardiac resynchronization therapy in advanced heart failure the multicenter InSync clinical study. Eur J Heart Fail. 2002;4(3):311-320. [pmid: 12034157].
Guidant Corporation, Cardiac Rhythm Management. Summary of safety and effectiveness CONTAK-CD CRT-D system including CONTAK CD CRT-D pulse generator model 1823, and software application model 2848 (version 3.1). [report] PMA P010012, 1–47. 2002.
Krahn A D, Snell L, Yee R, et al. Biventricular pacing improves quality of life and exercise tolerance in patients with heart failure and intraventricular conduction delay. Can J Cardiol. 2002;18(4):380-387. [pmid: 11992131].
Kuhlkamp V. Initial experience with an implantable cardioverter-defibrillator incorporating cardiac resynchronization therapy. J Am Coll Cardiol. 2003;39(5):790-797. [pmid: 11869843].
Leclercq C, Walker S, Linde C, et al. Comparative effects of permanent biventricular and right-univentricular pacing in heart failure patients with chronic atrial fibrillation. (MUSTIC AF). Eur Heart J. 2002;23:1780-1787. [pmid: 12419298].
Leclercq C, Victor F, Alonso C, et al. Comparative effects of permanent biventricular pacing for refractory heart failure in patients with stable sinus rhythm or chronic atrial fibrillation. Am J Cardiol. 2000;85(9):1154-1156. [pmid: 10781772].
Leclercq C, Alonso F, d'Allones FR, Boulmier D, de Place C, Carre F et al. [Effets à moyen terme de la stimulation multisite biventriculaire dans l'insuffisance cardiaque sévère]. Unpublished Work
Leclercq C, Cazeau S, Lellouche D, et al. Upgrading from right-ventricular pacing to biventricular pacing in previously paced patients with advanced heart failure: a randomized controlled study (RD-CHF trial). [abstract] Presented at the European Society of Cardiology, Vienna, Austria, September 1st, 2003.
Leon A R, Greenberg J M, Baker C M, et al. Cardiac resynchronization in patients with congestive heart failure and chronic atrial fibrillation: effect of upgrading to biventricular pacing after chronic right ventricular pacing. J Am Coll Cardiol. 2002;39(8):1258-1263. [pmid: 11955841].
Medtronic Inc. Summary of safety and effectiveness: Insync ICD model 7272 dual chamber implantable cardioverter defibrillator with biventricular pacing for cardiac resynchronization, Attain models 2187, 2188, 4189 leads. (MIRACLE ICD Trial). [Report] PMA P010031, 1–75. 12-3-2001.
Molhoek S G, Bax J J, Van Erven L, et al. Effectiveness of resynchronization therapy in patients with end-stage heart failure. Am J Cardiol. 2002;90(4):379-383. [pmid: 12161226].