# Reference List for Table C-1

Abraham W T. Cardiac resynchronization therapy for heart failure: Biventricular pacing and beyond. Curr Opin Cardiol. 2002;17(4):346-352. [pmid: 12151867].
Auricchio A, Stellbrink C, Sack S, et al. Long-term clinical effect of hemodynamically optimized cardiac resynchronization therapy in patients with heart failure and ventricular conduction delay (PATH CHF Trial). J Am Coll Cardiol. 2002;39(12):2026-2033. [pmid: 12084604].
Bristow M, et al. Comparison of medical therapy, pacing and defibrillation in heart failure (COMPANION Trial). Presented at the 52nd Annual Scientific Conference, American College of Cardiology, Chicago, Illinois, USA, March 31st: 2003.
Cazeau S, Leclercq C, Lavergne T, et al. Effects of multisite biventricular pacing in patients with heart failure and intraventricular conduction delay. (MUSTIC SR). N Engl J Med. 2001;344(12):873-880. [pmid: 11259720].
Garrigue S, Bordachar P, Reuter S, et al. Comparison of permanent left ventricular and biventricular pacing in patients with heart failure and chronic atrial fibrillation: prospective haemodynamic study. Heart. 2002;87(6):529-534. [pmid: 12010933]. [pmcid: 1767120].
Guidant Corporation, Cardiac Rhythm Management. Summary of safety and effectiveness CONTAK-CD CRT-D system including CONTAK CD CRT-D pulse generator model 1823, and software application model 2848 (version 3.1). [Report] PMA P010012, 1–47. 2002.
Leclercq C, Walker S, Linde C, et al. Comparative effects of permanent biventricular and right-univentricular pacing in heart failure patients with chronic atrial fibrillation. (MUSTIC AF). Eur Heart J. 2002;23:1780-1787. [pmid: 12419298].
Leclercq C, Cazeau S, Lellouche D, et al. Upgrading from right-ventricular pacing to biventricular pacing in previously paced patients with advanced heart failure: a randomized controlled study (RD-CHF trial). [abstract] Presented at the European Society of Cardiology, Vienna, Austria, September 1st, 2003.
Medtronic Inc. Summary of safety and effectiveness: Insync ICD model 7272 dual chamber implantable cardioverter defibrillator with biventricular pacing for cardiac resynchronization, Attain models 2187, 2188, 4189 leads. (MIRACLE ICD Trial). [report] PMA P010031, 1–75. 12-3-2001.