# Excluded Studies

There were five main reasons for exclusion: the study was not a CRT trial; the article was a review, a protocol, an editorial, or it did not report required outcomes.

1 Abraham W T. Cardiac resynchronization therapy for heart failure: Biventricular pacing and beyond. Curr Opin Cardiol. 2002;17(4):346-352. Review article. [pmid: 12151867].
2 Anonymous. Long term benefits of pacemaker-like device for heart failure patients. Can J Cardiol 2000;16 (4):538–39. News report
3 Auricchio A, Klein H U. Beyond expectations: a decade of positive results with cardiac resynchronization therapy for heart failure. Eur Heart J Supp. 2002;4(D):D95-D101. Review article.
4 Auricchio A, Spinelli J C, Trautmann S I, Kloss M. Effect of cardiac resynchronization therapy on ventricular remodeling. J Card Fail. 2002;8(2):S549-S555. No required outcomes. [pmid: 12555172].
5 Baumann LS, Kadhiresan VA, Yu Y, et al. Optimization of cardiac resynchronization therapy in heart failure patients by measuring transient cycle length changes. [abst] Eur Heart J 2001; 22, 443. No required outcomes
6 Bongiorni M G, Soldati E, Arena G, et al. Multicenter clinical evaluation of a new SSIR pacemaker. Pacing Clin Electrophysiol. 1992;15(11 Pt 2):1798-1803. Not a CRT trial. [pmid: 1279550].
7 Bordachar P, Garrigue S, Reuter S, et al. Hemodynamic assessment of right, left, and biventricular pacing by peak endocardial acceleration and echocardiography in patients with end-stage heart failure. Pacing Clin Electrophysiol. 2000;23(11 Pt 2):1726-1730. Not a CRT trial. [pmid: 11139910].
8 Breithardt G, Kuhn H, Hammel D, et al. Cardiac resynchronization therapy into the next decade: from the past to morbidity/mortality trials. Eur Heart J Suppl. 2002;4(D):D102-D110. Review article.
9 Butter C, Meisel E, Tebbenjohanns J, et al. Transvenous biventricular defibrillation halves energy requirements in patients. Circulation. 2001;104(21):2533-2538. Not a CRT trial. [pmid: 11714646].
10 Capucci A, Romano S, Puglisi A, et al. Dual chamber pacing with optimal AV delay in congestive heart failure: a randomized study. Europace. 1999;1(3):174-178. Not a CRT trial. [pmid: 11225793].
11 Cazeau S, Gras D, Lazarus A, et al. Multisite stimulation for correction of cardiac asynchrony. Heart. 2000;84(6):579-581. Editorial. [pmid: 11083728]. [pmcid: 1729514].
12 Cuzin B, Kirkorian G, Maisonneuve H. Cardiac pacemakers: When clinical evaluation lags behind technological progress. Int J Technol Assess Health Care. 2000;16(3):910-923. Review article. [pmid: 11028147].
13 De Marco T, Foster E, Schafer J, et al. Effect of chronic cardiac resynchronization on left ventricular remodeling and neurohormonal activation. [abst] J Am Coll Cardiol 37[2], 118A–119A. 2001. No required outcomes.
14 Filzmaier K, Sinha A M, Breithardt O A, et al. Short-term effects of cardiac resynchronization on brain natriuretic peptide release in patients with systolic heart failure and ventricular conduction disturbance. [abst]. J Am Coll Cardiol. 2002;39(5):111A-111A. No required outcomes.
15 Fonarow G C, Feliciano Z, Boyle N G, et al. Improved survival in patients with nonischemic advanced heart failure and syncope treated with an implantable cardioverter-defibrillator. Am J Cardiol. 2000;85(8):981-985. Not a CRT trial. [pmid: 10760339].
16 Gaita F, Bocchiardo M, Porciani M C, et al. Should stimulation therapy for congestive heart failure be combined with defibrillation backup?. Am J Cardiol. 2000;86(9 SUPPL. 1):165K-168K. Review article.
17 Gerber T C, Nishimura R A, Holmes D R Jr, J, et al. Left ventricular and biventricular pacing in congestive heart failure. Mayo Clin Proc. 2001;76(8):803-812. Review article. [pmid: 11499820].
18 Gold M R, Brockman R, Peters R W, et al. Acute hemodynamic effects of right ventricular pacing site and pacing mode in patients with congestive heart failure secondary to either ischemic or idiopathic dilated cardiomyopathy. Am J Cardiol. 2000;85(9):1106-1109. Not a CRT trial. [pmid: 10781760].
19 Greenberg J M, Baker C M, Mera F V, et al. Cardiac resynchronization improves ventricular function and symptoms of congestive heart failure in the absence of any mechanical atrial contribution. [abst]. J Am Coll Cardiol. 2002;39(5):77A-77A. No required outcomes.
20 Higgins S L, Pak J P, Barone J, et al. The first-year experience with the dual chamber ICD. Pace-Pacing Clin Electrophysiol. 2000;23(1):18-25. Not a CRT trial. [pmid: 10666749].
21 Hoppe U C, Erdmann E. Cardiac resynchronization in heart failure. Deutsche Medizinische Wochenschrift. 2002;127(13):677-681. Review article. [pmid: 11928059].
22 Kerwin W F, Botvinick E H, O'Connell J W, et al. Ventricular contraction abnormalities in dilated cardiomyopathy: effect of biventricular pacing to correct interventricular dyssynchrony. J Am Coll Cardiol. 2000;35(5):1221-1227. No required outcomes. [pmid: 10758964].
23 Kloss M, Auricchio A, Trautmann S, Klein H. Cardiac resynchronization therapy improves chronotropic response in patients with heart failure. [abst]. Eur Heart J. 2001;22:443-443. Retrospective review.
24 Leclercq C, Cazeau S, Ritter P, Daubert C. [Stimulation cardiaque et insuffisance cardiaque] Pacing and cardiac failure. Archives des Maladies du Coeur et des Vaisseaux. 1998;91(11):1389-1397. Review article. [pmid: 9864609].
25 Lupi G, Brignole M, Oddone D, et al. Effects of left ventricular pacing on cardiac performance and on quality of life in patients with drug refractory heart failure. Am J Cardiol. 1909;86(11):1267-1270. Not a CRT trial. [pmid: 11090807].
26 Meisel E, Rauwolf T, Burghardt M, Kappenberger L. [Pacemaker therapy of hypertrophic obstructive cardiomyopathy. PIC (Pacing in Cardiomyopathy) Study Group]. [German]. Herz. 2000;25(4):461-466. Not a CRT trial. [pmid: 10948782].
27 Morichika N, Okamoto M, Honda T, et al. Left ventricular wall motion analysis during ventricular pacing. J Cardiol. 1993;23(SUPPL. 37):85-88. Not a CRT trial.
28 Nagele H, Schomburg R, Petersen B, Rodiger W. Dual chamber pacing in patients with severe heart failure on beta blocker and amiodarone treatment: preliminary results of a randomised study. Heart (British Cardiac Society). 2002;87(6):566-567. Not a CRT trial. [pmid: 12010943]. [pmcid: 1767124].
29 Padelitti L, Porciani M C, Colella A, et al. Cardiac resynchronization reverses left ventricular remodeling and reduces cytokine activation in patients with dilated cardiomyopathy and left bundle branch block. [abst]. J Am Coll Cardiol. 2002;39(5):78A. No required outcomes.
30 Pappone C, Rosanio S, Oreto G, et al. Cardiac pacing in heart failure patients with left bundle branch block: Impact of pacing site for optimizing left ventricular resynchronization. Ital Heart J. 2000;1(7):464-469. No required outcomes. [pmid: 10933328].
31 Perrins E J, Morley C A, Chan S L, Sutton R. Randomised controlled trial of physiological and ventricular pacing. Br Heart J. 1983;50(2):112-117. Not a CRT trial. [pmid: 6349666]. [pmcid: 481382].
32 Peters R W, Gold M R. Pacing for patients with congestive heart failure and dilated cardiomyopathy. Cardiol Clin. 2000;18(1):55-66. Review article. [pmid: 10709685].
33 Shinke T, Takeuchi M, Takaoka H, Yokoyama M. Beneficial effects of heart rate reduction on cardiac mechanics and energetics in patients with left ventricular dysfunction. Japanese Circulation Journal. 1999;63(12):957-964. Not a CRT trial. [pmid: 10614841].
34 Stellbrink C, Sinha A M, Diem B, et al. Implantable cardioverter-defibrillators with or without cardiac resynchronization therapy - multiple therapy in a single device: a review with special reference to the PACMAN study. Eur Heart J Suppl. 2002;4(D):D88-D94. Review article.
35 Tatarchenko IP, Iskenderov BG, Koledinov VI. Results of 5-year follow-up of patients suffering from chronic circulatory insufficiency and having an implantable pacemaker. [abst] Kardiologiia 32[2], 45–48. 1992. Not a CRT trial.
36 Tavazzi L. Electrical stimulation of the failing heart: A new therapeutical strategy?. Eur Heart J Suppl. 2000;2(J):J2-J5. Editorial.
37 Tavazzi L. Ventricular pacing: A promising new therapeutic strategy in heart failure. For whom?. Eur Heart J. 2000;21(15):1211-1214. Editorial. [pmid: 10924309].
38 Toff W D, Skehan J D, De Bono D P, Camm A J. The United Kingdom pacing and cardiovascular events (UKPACE) trial. Heart. 1997;78(3):221-223. Protocol. [pmid: 9391280]. [pmcid: 484920].
39 Vogt P, Goy J J, Kuhn M, et al. Single versus double chamber rate responsive cardiac pacing: comparison by cardiopulmonary noninvasive exercise testing. Pacing Clin Electrophysiol. 1988;11(11 Pt 2):1896-1901. Not a CRT trial. [pmid: 2463564].
40 Walker S, Levy T M, Coats A J S, et al. on behalf of Imperial College Cardiac Electrophysiology Group. Bi-ventricular pacing in congestive cardiac failure: Current experience and future directions. Eur Heart J. 2000;21(11):884-889. Review article. [pmid: 10806011].
41 Walker S, Levy T M, Rex S, et al. Usefulness of suppression of ventricular arrhythmia by biventricular pacing in severe congestive cardiac failure. Am J Cardiol. 2000;86(2):231-233. No required outcomes. [pmid: 10913492].
42 Wilkoff B, Cook J R, Epstein A E, et al. Dual-chamber pacing or ventricular backup pacing in patients with an implantable defibrillator: the Dual Chamber and VVI Implantable Defibrillator (DAVID) Trial. JAMA. 2002;288(24):3115-3123. Not a CRT trial. [pmid: 12495391].