# Included Studies

### Efficacy Review

1 Abraham W T, Fisher W G, Smith A L, et al. Cardiac resynchronization in chronic heart failure. N Engl J Med. 2002;346(24):1845-53. [pmid: 12063368].
2 Auricchio A, Stellbrink C, Sack S, et al. Long-term clinical effect of hemodynamically optimized cardiac resynchronization therapy in patients with heart failure and ventricular conduction delay. J Am Coll Cardiol. 2002;39(12):2026-33. [pmid: 12084604].
3 Bristow MR, et al. Comparison of medical therapy, pacing and defibrillation in heart failure (COMPANION Trial). Presented at the 52nd Annual Scientific Conference, American College of Cardiology, Chicago, Il, USA, March 31st: 2003.
4 Cazeau S, Leclercq C, Lavergne T, et al. Effects of multisite biventricular pacing in patients with heart failure and intraventricular conduction delay. N Engl J Med. 2001;344(12):873-80. [pmid: 11259720].
5 Garrigue S, Bordachar P, Reuter S, et al. Comparison of permanent left ventricular and biventricular pacing in patients with heart failure and chronic atrial fibrillation: prospective haemodynamic study. Heart. 2002;87(6):529-534. [pmid: 12010933]. [pmcid: 1767120].
6 Guidant Corporation, Cardiac Rhythm Management. Summary of safety and effectiveness CONTAK-CD CRT-D system including CONTAK CD CRT-D pulse generator model 1823, and software application model 2848 (version 3.1). PMA P010012, 1–47. 2002
7 Leclercq C, Walker S, Linde C, et al. Comparative effects of permanent biventricular and right-univentricular pacing in heart failure patients with chronic atrial fibrillation. Eur Heart J 2002;1780–87
8 Medtronic, Inc. Summary of Safety and Effectiveness: InSync ICD Model 7272 dual chamber implantable cardioverter defibrillator with biventricular pacing for cardiac resynchronization, Attain Models 2187, 2188, 4189 leads. PMA: P010031. Food and Drug Administration, Dec 3, 2001

### Safety Review

1 Abraham W T, Fisher W G, Smith A L, et al. Cardiac resynchronization in chronic heart failure. N Engl J Med. 2002;346(24):1845-1853. [pmid: 12063368].
2 Auricchio A, Stellbrink C, Sack S, et al. Long-term clinical effect of hemodynamically optimized cardiac resynchronization therapy in patients with heart failure and ventricular conduction delay. J Am Coll Cardiol. 2002;39(12):2026-33. [pmid: 12084604].
3 Bristow MR, et al. Comparison of medical therapy, pacing and defibrillation in heart failure (COMPANION Trial). Presented at the 52nd Annual Scientific Conference, American College of Cardiology, Chicago, Il, USA, March 31st: 2003
4 Cazeau S, Leclercq C, Lavergne T, et al. Effects of multisite biventricular pacing in patients with heart failure and intraventricular conduction delay (MUSTIC SR). N Engl J Med. 2001;344(12):873-80. [pmid: 11259720].
5 Cazeau S, Ritter P, Lazarus A, et al. Multisite pacing for end-stage heart failure: early experience. PACE. 1996;19:1748-57. [pmid: 8945034].
6 Filho M M, Pedrosa A A, Costa R, et al. Biventricular pacing improves clinical behavior and reduces prevalence of ventricular arrhythmia in patients with heart failure. Arq Bras Cardiol. 2002;78(1):110-3. [pmid: 11826352].
7 Gras D, Leclercq C, Tang A S, et al. Cardiac resynchronization therapy in advanced heart failure the multicenter InSync clinical study. (InSync) Eur J Heart Fail. 2002;4(3):311-20.
8 Guidant Corporation, Cardiac Rhythm Management. Summary of safety and effectiveness CONTAK-CD CRT-D system including CONTAK CD CRT-D pulse generator model 1823, and software application model 2848 (version 3.1). PMA P010012, 1–47. 2002
9 Krahn A D, Snell L, Yee R, et al. Biventricular pacing improves quality of life and exercise tolerance in patients with heart failure and intraventricular conduction delay. Can J Cardiol. 2002;18(4):380-7. [pmid: 11992131].
10 Kuhlkamp V. Initial experience with an implantable cardioverter-defibrillator incorporating cardiac resynchronization therapy. J Am Coll Cardiol. 2003;39(5):790-7. [pmid: 11869843].
11 Leclercq C, Victor F, Alonso C, et al. Comparative effects of permanent biventricular pacing for refractory heart failure in patients with stable sinus rhythm or chronic atrial fibrillation. Am J Cardiol. 2000;85(9):1154-6. [pmid: 10781772].
12 Leclercq C, Walker S, Linde C, et al. Comparative effects of permanent biventricular and right-univentricular pacing in heart failure patients with chronic atrial fibrillation. (MUSTIC AF) Eur Heart J. 2002;1780–7.
13 Leclercq C, Alonso F, d'Allones FR, et al. [Effets à moyen terme de la stimulation multisite biventriculaire dans l'insuffisance cardiaque sévère]. Unpublished Work
14 Leon A R, Greenberg J M, Baker C M, et al. Cardiac resynchronization in patients with congestive heart failure and chronic atrial fibrillation: effect of upgrading to biventricular pacing after chronic right ventricular pacing. J Am Coll Cardiol. 2002;39(8):1258-63. [pmid: 11955841].
15 Medtronic Inc. Summary of Safety and Effectiveness: InSync ICD Model 7272 dual chamber implantable cardioverter defibrillator with biventricular pacing for cardiac resynchronization, Attain Models 2187, 2188, 4189 leads. PMA: P010031. Food and Drug Administration, Dec 3, 2001 (MIRACLE ICD)
16 Molhoek S G, Bax J J, Van Erven L, et al. Effectiveness of resynchronization therapy in patients with end-stage heart failure. Am J Cardiol. 2002;90(4):379-83. [pmid: 12161226].