# References

1 American Heart Association. Heart Disease and Stroke Statistics - 2003 Update. Dallas, TX: American Heart Association, 2002.
2 Cowie M R, Mosterd A, Wood D A, et al. The epidemiology of heart failure. Eur Heart J. 1997;18(2):208-225. [pmid: 9043837].
3 Heart and Stroke Foundation Canada. The changing face of heart disease and stroke in Canada. Ottawa: Heart and Stroke Foundation Canada, 2000.
4 Redfield M M, Jacobsen S J, Burnett J C Jr, et al. Burden of systolic and diastolic ventricular dysfunction in the community: Appreciating the scope of the heart failure epidemic. JAMA. 2003;289(2):194-202. [pmid: 12517230].
5 Lloyd-Jones D M, Larson M G, Leip E P, et al. Lifetime risk for developing congestive heart failure: The Framingham Heart Study. Circulation. 2002;106(24):3068-3072. [pmid: 12473553].
6 MacIntyre K, Capewell S, Stewart S, et al. Evidence of improving prognosis in heart failure: Trends in case fatality in 66,547 patients hospitalized between 1986 and 1995. Circulation. 2000;102(10):1126-1131. [pmid: 10973841].
7 Jong P, Vowinckel E, Liu P P, et al. Prognosis and determinants of survival in patients newly hospitalized for heart failure: A population-based study. Arch Intern Med. 2002;162(15):1689-1694. [pmid: 12153371].
8 Poole-Wilson P A, Uretsky B F, Thygesen K, et al. Mode of death in heart failure: findings from the ATLAS trial. Heart. 2003;89(1):42-48. [pmid: 12482789]. [pmcid: 1767481].
9 Massie B M. 15 years of heart-failure trials: What have we learned?. Lancet. 1998;352(Suppl 1):SI29-SI33. [pmid: 9736477].
10 Hunt S A, Baker D W, Chin M H, et al. ACC/AHA Guidelines for the Evaluation and Management of Chronic Heart Failure in the Adult: Executive Summary A Report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (Committee to Revise the 1995 Guidelines for the Evaluation and Management of Heart Failure). Circulation. 2001;104(24):2996-3007. [pmid: 11739319].
11 Gheorghiade M, Bonow R O. Chronic heart failure in the United States: A manifestation of coronary artery disease. Circulation. 1998;97(3):282-289. [pmid: 9462531].
12 HFSA guidelines for the management of patients with heart failure due to left ventricular systolic dysfunction--pharmacological approaches. Congest Heart Fail 2000; 6(1): 11–39
13 Liu P, Arnold M, Belenkie I, et al. The 2001 Canadian Cardiovascular Society consensus guideline update for the management and prevention of heart failure. Can J Cardiol. 2001;17(Suppl E):5E-25E.
14 Ho K K, Anderson K M, Kannel W B, et al. Survival after the onset of congestive heart failure in Framingham Heart Study subjects. Circulation. 1993;88(1):107-115. [pmid: 8319323].
15 Gillum R F. Epidemiology of heart failure in the United States. Am Heart J. 1993;126(4):1042-1047. [pmid: 8213434].
16 Dries D L, Exner D V, Gersh B J, et al. Racial differences in the outcome of left ventricular dysfunction. N Engl J Med. 1999;340(8):609-616. [pmid: 10029645].
17 Shindler D M, Kostis J B, Yusuf S, et al. Diabetes mellitus, a predictor of morbidity and mortality in the Studies of Left Ventricular Dysfunction (SOLVD) Trials and Registry. Am J Cardiol. 1996;77(11):1017-1020. [pmid: 8644628].
18 Ezekowitz J A, McAlister F A, Armstrong P W. Anemia is common in heart failure and is associated with poor outcomes: insights from a cohort of 12 065 patients with new-onset heart failure. Circulation. 2003;107(2):223-225. [pmid: 12538418].
19 Dries D L, Exner D V, Domanski M J, et al. The prognostic implications of renal insufficiency in asymptomatic and symptomatic patients with left ventricular systolic dysfunction. J Am Coll Cardiol. 2000;35(3):681-689. [pmid: 10716471].
20 Drazner M H, Rame J E, Stevenson L W, et al. Prognostic importance of elevated jugular venous pressure and a third heart sound in patients with heart failure. N Engl J Med. 2001;345(8):574-581. [pmid: 11529211].
21 Lee W H, Packer M. Prognostic importance of serum sodium concentration and its modification by converting-enzyme inhibition in patients with severe chronic heart failure. Circulation. 1986;73(2):257-267. [pmid: 3002660].
22 Swedberg K, Eneroth P, Kjekshus J, et al. Hormones regulating cardiovascular function in patients with severe congestive heart failure and their relation to mortality. CONSENSUS Trial Study Group. Circulation. 1990;82(5):1730-1736. [pmid: 2225374].
23 Tsutamoto T, Wada A, Maeda K, et al. Attenuation of compensation of endogenous cardiac natriuretic peptide system in chronic heart failure: prognostic role of plasma brain natriuretic peptide concentration in patients with chronic symptomatic left ventricular dysfunction. Circulation. 1997;96(2):509-516. [pmid: 9244219].
24 Cohn J N, Johnson G R, Shabetai R, et al. Ejection fraction, peak exercise oxygen consumption, cardiothoracic ratio, ventricular arrhythmias, and plasma norepinephrine as determinants of prognosis in heart failure. The V-HeFT VA Cooperative Studies Group. Circulation. 1993;87(Suppl 6):VI5-V16. [pmid: 8500240].
25 Eichhorn E J. Prognosis determination in heart failure. Am J Med. 2001;110(Suppl 7A):14S-36S. [pmid: 11334772].
26 Cohn J N, Archibald D G, Ziesche S, et al. Effect of vasodilator therapy on mortality in chronic congestive heart failure. Results of a Veterans Administration Cooperative Study. N Engl J Med. 1986;314(24):1547-1552. [pmid: 3520315].
27 Cohn J N, Johnson G, Ziesche S, et al. A comparison of enalapril with hydralazine-isosorbide dinitrate in the treatment of chronic congestive heart failure. N Engl J Med. 1991;325(5):303-310. [pmid: 2057035].
28 The CONSENSUS Trial Study Group. Effects of enalapril on mortality in severe congestive heart failure. Results of the Cooperative North Scandinavian Enalapril Survival Study (CONSENSUS). N Engl J Med. 1987;316(23):1429-1435. [pmid: 2883575].
29 Garg R, Yusuf S. Overview of randomized trials of angiotensin-converting enzyme inhibitors on mortality and morbidity in patients with heart failure. Collaborative Group on ACE Inhibitor Trials. JAMA. 1995;273(18):1450-1456. [pmid: 7654275].
30 Flather M D, Yusuf S, Kober L, et al. Long-term ACE-inhibitor therapy in patients with heart failure or left-ventricular dysfunction: a systematic overview of data from individual patients. The Lancet. 2000;355(9215):1575-1581. [pmid: 10821360].
31 Brophy J M, Joseph L, Rouleau J L. Beta-blockers in congestive heart failure. A Bayesian meta-analysis. Ann Intern Med. 2001;134(7):550-560. [pmid: 11281737].
32 Lechat P, Packer M, Chalon S, et al. Clinical effects of adrenergic blockade in chronic heart failure: A meta-analysis of double-blind, placebo-controlled, randomized trials. Circulation. 1998;98(12):1184-1191. [pmid: 9743509].
33 Cohn J N, Tognoni G. A randomized trial of the angiotensin-receptor blocker valsartan in chronic heart failure. N Engl J Med. 2001;345(23):1667-75. [pmid: 11759645].
34 Jong P, Demers C, McKelvie R S, et al. Angiotensin receptor blockers in heart failure: meta-analysis of randomized controlled trials. J Am Coll Cardiol. 2002;39(3):463-470. [pmid: 11823085].
35 Medtronic Inc. Summary of safety and effectiveness: Medtronic InSync biventricular pacing system including the Insync model 8040, pulse generator, attain LV model 2187 and attain CS model 2188 leads (MIRACLE Trial). PMA: P010015, 9–51. 2001.
36 Medtronic Inc. Summary of safety and effectiveness: Insync ICD model 7272 dual chamber implantable cardioverter defibrillator with biventricular pacing for cardiac resynchronization, Attain models 2187, 2188, 4189 leads. (MIRACLE ICD Trial). PMA P010031, 1–75. 12-3-2001.
37 The Digitalis Investigation Group. The effect of digoxin on mortality and morbidity in patients with heart failure. N Engl J Med. 1997;336(8):525-533. [pmid: 9036306].
38 Feenstra J, Heerdink E R, Grobbee D E, et al. Association of nonsteroidal anti-inflammatory drugs with first occurrence of heart failure and with relapsing heart failure: The Rotterdam Study. Arch Int Med. 2002;162(3):265-270. [pmid: 11822918].
39 Tsuyuki R T, McKelvie R S, Arnold J M, et al. Acute precipitants of congestive heart failure exacerbations. Arch Intern Med. 2001;161(19):2337-2342. [pmid: 11606149].
40 Steinbrook R. Patients with multiple chronic conditions--how many medications are enough?. N Engl J Med. 1998;338(21):1541-1542. [pmid: 9593796].
41 McAlister F A, Lawson F M, Teo K K, et al. A systematic review of randomized trials of disease management programs in heart failure. Am J Med. 2001;110(5):378-384. [pmid: 11286953].
42 Belardinelli R, Georgiou D, Cianci G, et al. Randomized, controlled trial of long-term moderate exercise training in chronic heart failure: Effects on functional capacity, quality of life, and clinical outcome. Circulation. 1999;99(9):1173-1182. [pmid: 10069785].
43 McKelvie R S, Teo K K, Roberts R, et al. Effects of exercise training in patients with heart failure: the Exercise Rehabilitation Trial (EXERT). Am Heart J. 2002;144(1):23-30. [pmid: 12094184].
44 Rose E A, Gelijns A C, Moskowitz A J, et al. Long-term mechanical left ventricular assistance for end-stage heart failure. N Engl J Med. 2001;345(20):1435-1443. [pmid: 11794191].
45 Baker D W, Jones R, Hodges J, et al. Management of heart failure. III. The role of revascularization in the treatment of patients with moderate or severe left ventricular systolic dysfunction. JAMA. 1994;272(19):1528-1534. [pmid: 7966846].
46 Tandon P, McAlister FA, Tsuyuki RT et al. The use of beta-blockers in a heart function clinic: insights into dosing, tolerance, and outcomes. Arch Intern Med; 2003; (in press).
47 Ezekowitz J A, Armstrong P W, McAlister F A. Implantable cardioverter defibrillators in primary and secondary prevention: a systematic review of randomized, controlled trials. Ann Intern Med. 2003;138(6):445-452. [pmid: 12639076].
48 Baldasseroni S, Opasich C, Gorini M, et al. Left bundle branch block is associated with increased 1-year sudden and total mortality rate in 5517 outpatients with congestive heart failure: a report from the Italian network on congestive heart failure. Am Heart J. 2002;143(3):398-405. [pmid: 11868043].
49 Aaronson K D, Schwartz J S, Chen T M, et al. Development and prospective validation of a clinical index to predict survival in ambulatory patients referred for cardiac transplant evaluation. Circulation. 1997;95(12):2660-2667. [pmid: 9193435].
50 Shamim W, Francis D P, Yousufuddin M, et al. Intraventricular conduction delay: A prognostic marker in chronic heart failure. Int J Cardiol. 1999;70(2):171-178. [pmid: 10454306].
51 Nishimura R A, Hayes D L, Holmes D R Jr, et al. Mechanism of hemodynamic improvement by dual-chamber pacing for severe left ventricular dysfunction: an acute Doppler and catheterization hemodynamic study. J Am Coll Cardiol. 1995;25(2):281-288. [pmid: 7829778].
52 Gold M R, Feliciano Z, Gottlieb S S, et al. Dual-chamber pacing with a short atrioventricular delay in congestive heart failure: a randomized study. J Am Coll Cardiol. 1995;26(4):967-973. [pmid: 7560625].
53 Auricchio A, Stellbrink C, Block M, et al. Effect of pacing chamber and atrioventricular delay on acute systolic function of paced patients with congestive heart failure. The Pacing Therapies for Congestive Heart Failure Study Group. The Guidant Congestive Heart Failure Research Group. Circulation. 1999;99(23):2993-3001. [pmid: 10368116].
54 Kass D A, Chen C H, Curry C, et al. Improved left ventricular mechanics from acute VDD pacing in patients with dilated cardiomyopathy and ventricular conduction delay. Circulation. 1999;99(12):1567-1573. [pmid: 10096932].
55 Leclercq C, Cazeau S, Le Breton H, et al. Acute hemodynamic effects of biventricular DDD pacing in patients with end-stage heart failure. J Am Coll Cardiol. 1998;32(7):1825-1831. [pmid: 9857858].
56 Nelson G S, Berger R D, Fetics B J, et al. Left ventricular or biventricular pacing improves cardiac function at diminished energy cost in patients with dilated cardiomyopathy and left bundle branch block. Circulation. 2000;102(25):3053-3059. [pmid: 11120694].
57 Cazeau S, Ritter P, Bakdach S, et al. Four chamber pacing in dilated cardiomyopathy. Pacing Clin Electrophysiol. 1994;17(11 Pt 2):1974-1979. [pmid: 7845801].
58 Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: Is blinding necessary?. Control Clin Trials. 1996;17:1-12. [pmid: 8721797].
59 Downs S H, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of healthcare interventions. J Epidemiol Community Health. 1998;52(6):377-384. [pmid: 9764259].
60 Bristow Comparison of medical therapy, pacing and defibrillation in heart failure (COMPANION Trial). Presented at the 52nd Annual Scientific Conference, American College of Cardiology, Chicago, Illinois, USA, March 31st: 2003.
61 Abraham W T, Fisher W G, Smith A L, et al. Cardiac resynchronization in chronic heart failure. N Engl J Med. 2002;346(24):1845-1853. [pmid: 12063368].
62 Auricchio A, Stellbrink C, Sack S, et al. Long-term clinical effect of hemodynamically optimized cardiac resynchronization therapy in patients with heart failure and ventricular conduction delay (PATH CHF Trial). J Am Coll Cardiol. 2002;39(12):2026-2033. [pmid: 12084604].
63 Follmann D, Elliott P, Suh I, et al. Variance imputation for overviews of clinical trials with continuous response. J Clin Epidemiol. 1992;45(7):769-773. [pmid: 1619456].
64 Stata Corporation.Version 7.0. Stata Corporation 2001.
65 S-plus 6.0. S-plus 6 0 2003.
66 Parmar M K B, Torri V, Stewart L. Extracting summary statistics to perform meta-analyses of the published literature for survival endpoints. Stat Med. 1998;17:2815-2834. [pmid: 9921604].
67 DerSimonian R, Laird N. Meta-analysis in clinical trials. Contr Clin Trials. 1986;7:177-188.
68 Hedges LV & Olkin I. Statistical Methods for Meta-Analysis. San Diego: Academic Press, Inc., 1985.
69 Higgins J P T, Thompson S G. Quanitifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1538-1558.
70 Garrigue S, Bordachar P, Reuter S, et al. Comparison of permanent left ventricular and biventricular pacing in patients with heart failure and chronic atrial fibrillation: prospective haemodynamic study. Heart. 2002;87(6):529-534. [pmid: 12010933]. [pmcid: 1767120].
71 Curtin F, Altman D G, Elbourne D. Meta-analysis combining parallel and cross-over trials. I: Continuous outcomes. Stat Med. 2002;21:2131-2144. [pmid: 12210629].
72 Gold MR, Siegel JE, Russell LB, et al. : Summary Recommendations. In: Gold MR, Siegel JE, Russell LB, Weinstein MC, editors. Cost-effectiveness in Health and Medicine. New York: Oxford University Press, 1996: 425. Appendix A
73 Guidant Corporation, Cardiac Rhythm Management. Summary of safety and effectiveness CONTAK-CD CRT-D system including CONTAK CD CRT-D pulse generator model 1823, and software application model 2848 (version 3.1). PMA P010012, 1–47. 2002.
74 Cazeau S, Leclercq C, Lavergne T, et al. Effects of multisite biventricular pacing in patients with heart failure and intraventricular conduction delay. (MUSTIC SR). N Engl J Med. 2001;344(12):873-880. [pmid: 11259720].
75 Leclercq C, Walker S, Linde C, et al. Comparative effects of permanent biventricular and right-univentricular pacing in heart failure patients with chronic atrial fibrillation. (MUSTIC AF). Eur Heart J. 2002;23:1780-1787. [pmid: 12419298].
76 Beck J R, Pauker S G, Gottlieb J E, et al. A convenient approximation of life expectancy (the “DEALE”). II. Use in medical decision-making. Am J Med. 1982;73(6):889-897. [pmid: 6983298].
77 Beck J R, Kassirer J P, Pauker S G. A convenient approximation of life expectancy (the “DEALE”). I. Validation of the method. Am J Med. 1982;73(6):883-888. [pmid: 7148881].
78 Gold MR, Siegel JE, Russell LB, et al. Summary Recommendations. Cost-effectiveness in health and medicine. New York: Oxford University Press, 1996: 425.
79 Owens D K, Sanders G D, Harris R A, et al. Cost-effectiveness of implantable cardioverter defibrillators relative to amiodarone for prevention of sudden cardiac death. Ann Intern Med. 1997;126(1):1-12. [pmid: 8992917].
80 Torrance G W. Measurement of health state utilities for economic appraisal. J Health Econ. 1986;5(5):1-30. [pmid: 10311607].
81 Feeny D, Furlong W, Torrance G W, et al. Multiattribute and single-attribute utility functions for the health utilities index mark 3 system. Med Care. 2002;40(2):113-128. [pmid: 11802084].
82 Kaul P, Davidson-Ray L, Cowper P A, et al. Economic burden of non-ischemic congestive heart failure: Evidence from PRAISE 2 [Abstract]. J Am Coll Cardiol. 2003;41(Suppl A):535A.
83 Nichol G, Valenzuela T, Roe D, et al. Potential cost-effectiveness of defribrillation by targeted responders in public settings. Circ J 2003; in press.
84 National Center for Health Statistics, Centers for Disease Control and Prevention, U.S. Department of Health and Human Services. U.S. Decennial Life Tables for 1998. Hyattsville, MD: Centers for Disease Control and Prevention 2001. Available from http://www.sicr.org/scdheft/index.html. Accessed February 5, 2003
85 Doubilet P, Begg C B, Weinstein M C, et al. Probabilistic sensitivity analysis using Monte Carlo simulation. A practical approach. Med Decis Making. 1985;5(2):157-177. [pmid: 3831638].
86 Critchfield G C, Willard K E. Probabilistic analysis of decision trees using Monte Carlo simulation. Med Decis Making. 2003;6(2):85-92. [pmid: 3702625].
87 Christensen R. Data distributions: A Statistical Handbook. Lincoln, MA: Entropy Ltd., 1989.
88 Hirth R A, Chernew M E, Miller E, et al. Willingness to pay for a quality-adjusted life year: in search of a standard. Med Decis Making. 2000;20(3):332-342. [pmid: 10929856].
89 Briggs A, Sculpher M, Buxton M. Uncertainty in the economic evaluation of healthcare technologies: the role of sensitivity analysis. Health Econ. 1994;3(3):95-104. [pmid: 8044216].
90 Sox HCJr, Blatt MA, Higgins MC, et al. Medical Decision Making. Toronto: Butterworth, 1988.
91 Uretsky B F, Thygesen K, Armstrong P W, et al. Acute coronary findings at autopsy in heart failure patients with sudden death: results from the assessment of treatment with lisinopril and survival (ATLAS) trial. Circulation. 2000;102(6):611-616. [pmid: 10931799].
92 Owens D K, Sanders G D, Harris R A, et al. Cost-effectiveness of implantable cardioverter-defibrillators relative to amiodarone for prevention of sudden cardiac death. Ann Intern Med. 1997;126(1):1-12. [pmid: 8992917].
93 Medtronic Inc. Summary of safety and effectiveness: InSync ICD model 7272 dual chamber implantable cardioverter defibrillator with resynchronization therapy and the model 9969 application software (MIRACLE ICD Trial). PMA P010031, 1–55. 2002
94 Young J B, Abraham W T, Smith A L, et al. Combined cardiac resynchronization and implantable cardioversion defibrillation in advanced chronic heart failure: The MIRACLE ICD Trial. JAMA. 2003;289(20):2685-2694. [pmid: 12771115].
95 Bristow M R, Feldman A M, Saxon L A. Heart failure management using implantable devices for ventricular resynchronization: Comparison of medical therapy, pacing, and defibrillation in chronic heart failure (COMPANION trial). J Cardiac Fail. 2000;6(3):276-285.
96 Leclercq C, Victor F, Alonso C, et al. Comparative effects of permanent biventricular pacing for refractory heart failure in patients with stable sinus rhythm or chronic atrial fibrillation. Am J Cardiol. 2000;85(9):1154-1156. [pmid: 10781772].
97 Krum H, Gilbert R E. Demographics and concomitant disorders in heart failure. Lancet. 2003;362:147-58. [pmid: 12867118].
98 Filho M M, Pedrosa A A, Costa R, et al. Biventricular pacing improves clinical behavior and reduces prevalence of ventricular arrhythmia in patients with heart failure. Arq Bras Cardiol. 2002;78(1):110-113. [pmid: 11826352].
99 Cazeau S, Ritter P, Lazarus A, et al. Multisite pacing for end-stage heart failure: early experience. PACE. 1996;19:1748-1757. [pmid: 8945034].
100 Gras D, Leclercq C, Tang A S, et al. Cardiac resynchronization therapy in advanced heart failure the multicenter InSync clinical study. Eur J Heart Fail. 2002;4(3):311-320. [pmid: 12034157].
101 Krahn A D, Snell L, Yee R, et al. Biventricular pacing improves quality of life and exercise tolerance in patients with heart failure and intraventricular conduction delay. Can J Cardiol. 2002;18(4):380-387. [pmid: 11992131].
102 Kuhlkamp V. Initial experience with an implantable cardioverter-defibrillator incorporating cardiac resynchronization therapy. J Am Coll Cardiol. 2003;39(5):790-797. [pmid: 11869843].
103 Molhoek S G, Bax J J, Van Erven L, et al. Effectiveness of resynchronization therapy in patients with end-stage heart failure. J Am Coll Cardiol. 2002;90(4):379-383.
104 Leclercq C, Alonso F, d'Allones FR, et al. [Effets à moyen terme de la stimulation multisite biventriculaire dans l'insuffisance cardiaque sévère]. Unpublished Work.
105 Cazeau S, Gras D, Lazarus A, et al. Multisite stimulation for correction of cardiac asynchrony. Heart. 2000;84(6):579-581. [pmid: 11083728]. [pmcid: 1729514].
106 Leon A R, Greenberg J M, Baker C M, et al. Cardiac resynchronization in patients with congestive heart failure and chronic atrial fibrillation: effect of upgrading to biventricular pacing after chronic right ventricular pacing. J Am Coll Cardiol. 2002;39(8):1258-1263. [pmid: 11955841].
107 Leclercq C, Cazeau S, Ritter P, et al. A pilot experience with permanent biventricular pacing to treat advanced heart failure. Am Heart J. 2000;140(6):862-870. [pmid: 11099989].
108 Abraham W T. Cardiac resynchronization therapy for heart failure: Biventricular pacing and beyond. Curr Opinion Cardiol. 2002;17(4):346-352.
109 Rector T S, Cohn J N. Assessment of patient outcome with the Minnesota Living with Heart Failure questionnaire: Reliability and validity during a randomized, double-blind, placebo-controlled trial of pimobendan. Am Heart J. 1992;124:1017-1025. [pmid: 1529875].
110 Rector T S, Johnson G, Dunkman B, et al. Evaluation by patients with heart failure of the effects of enalapril compared with hydralazine plus isosorbide dinitrate on quality of life. Circulation. 1993;87:71-77.
111 Rector TS, Kubo SH, Cohn JN. Patients' self-assessment of their congestive heart failure- Part 2: Content, reliability, and validity of a new measure, The Minnesota Living with Heart Failure Questionnaire. Heart Fail 1987;198–208.
112 Boehmer J P, DeMarco T, Jaski B E, et al. Why ICD patients with heart failure (Class II–IV) are hospitalized: Do the reasons differ for patients who are treated with cardiac resynchronization therapy? [Abstract]. J Am Coll Cardiol. 2002;39(5):159A.
113 Higgins S L, Yong P, Sheck D, et al. Biventricular pacing diminishes the need for implantable cardioverter defibrillator therapy. Ventak CHF Investigators. J Am Coll Cardiol. 2000;36(3):824-827. [pmid: 10987605].
114 Saxon L A, Boehmer J P, Hummel J, et al. Biventricular pacing in patients with congestive heart failure: Two prospective randomized trials. The VIGOR CHF and VENTAK CHF Investigators. Am J Cardiol. 1999;83(5B):120D-123D. [pmid: 10073799].
115 Saxon L A, De Marco T, Schafer J, et al. Effects of long-term biventricular stimulation for resynchronization on echocardiographic measures of remodeling. Circulation. 2002;105(11):1304-1310. [pmid: 11901040].
116 Gras D, Mabo P, Tang T, et al. Multisite pacing as a supplemental treatment of congestive heart failure: Preliminary results of the Medtronic Inc. InSync Study. Pacing & Clinical Electrophysiol. 1998;21(11 Pt 2):2249-2255.
117 Gras D, Cazeau S, Ritter P, et al. Long term results of cardiac resynchronization for heart failure patients: The InSync Clinical Trial. [Abstract]. Circulation. 1999;100(18):2714.
118 Gras D, Cazeau S, Mabo P, et al. Long-term benefit of cardiac resynchronization in heart failure patients: The 12 month results of the InSync trial. [Abstract]. J Am Coll Cardiol. 2000;35(2):230A. [pmid: 10636285].
119 Gras D, Mabo P, Bucknall C, et al. Responders and nonresponders to cardiac resynchronization therapy: Results from the InSync trial. J Am Coll Cardiol. 2000;35(2):230A. [pmid: 10636285].
120 Tang A S L, Gras D, Mabo P, et al. Mortality and outcome differences between survivors and nonsurvivors in the InSync cardiac resynchronization trial. [Abstract]. Circulation. 1999;100(18):2715.
121 Zardini M, Tritto M, Bargiggia G, et al. The InSync-Italian Registry: analysis of clinical outcome and considerations on the selection of candidates to left ventricular resynchronization. Eur Heart J Supp. 2000;2(J):J16-J22.
122 Abraham W T. Rationale and design of a randomized clinical trial to assess the safety and efficacy of cardiac resynchronization therapy in patients with advanced heart failure: The Multicenter InSync Randomized Clinical Evaluation (MIRACLE). J Cardiac Fail. 2000;6(4):369-380.
123 Abraham W T, Fisher W, Smith A, et al. Cardiac resynchronization therapy reduces morbidity in patients with moderate to severe systolic heart failure and intraventricular conduction delays. [Abstract]. J Am Coll Cardiol. 2002;39(5):171A.
124 Abraham W T, Fisher W, Smith A, et al. Long-term improvement in functional status, quality of life and exercise capacity with cardiac resynchronization therapy: The MIRACLE Trial experience. [Abstract]. J Am Coll Cardiol. 2002;39(5):159A.
125 Aranda J M, Curtis A B, Conti J B, Peterson-Stejskal S. Do heart failure patients with right bundle branch block benefit from cardiac resynchronization therapy? Analysis of the MIRACLE study. [Abstract]. J Am Coll Cardiol. 2002;39(5):96A. [pmid: 11755293].
126 Packer M, Abraham W T. Effect of cardiac resynchronization on a composite clinical status endpoint in patients with chronic heart failure: Results of the MIRACLE trial. [Abstract]. Circulation. 2001;104(17):1995.
127 Sutton M G S, Plappert T, Abraham W T, et al. Cardiac resynchronization improves diastolic ventricular function in advanced heart failure: The MIRACLE trial. [Abstract]. Circulation. 2001;104(17):2920.
128 Wagoner L E, Zengel P W, Abraham W T, et al. Cardiac resynchronization therapy with the InSync stimulation system improves exercise performance in patients with heart failure: MIRACLE trial substudy results. [Abstract]. Circulation. 2001;104(17):2919.
129 Linde C, Leclercq C, Rex S, et al. Long-term benefits of biventricular pacing in congestive heart failure: results from the MUltisite STimulation in cardiomyopathy (MUSTIC) study. J Am Coll Cardiol. 2002;40(1):111-118. [pmid: 12103264].
130 Auricchio A, Klein H, Spinelli J. Pacing for heart failure: selection of patients, techniques and benefits. Eur J Heart Fail. 1999;1(3):275-279. [pmid: 10935675].
131 Auricchio A, Ding J, Spinelli J C, et al. Cardiac resynchronization therapy restores optimal atrioventricular mechanical timing in heart failure patients with ventricular conduction delay. J Am Coll Cardiol. 2002;39(7):1163-1169. [pmid: 11923041].
132 Baumann L S, Kadhiresan V A, Yu Y, et al. Optimization of cardiac resynchronization therapy in heart failure patients by measuring transient cycle length changes. [Abstract]. Eur Heart J. 2001;22:443.
133 Cuesta F, Sack S, Auricchio A, et al. Long-term benefit of cardiac resynchronization therapy in heart failure patients: results of the PATH-CHF study. [Abstract]. Eur Heart J. 2001;22:130.
134 Cuesta F, Stellbrink C, Auricchio A, et al. Cardiac resynchronization therapy reduces heart failure hospitalization in the PATH-CHF study. [Abstract]. Eur Heart J. 2001;22:441.
135 Huth C, Friedl A, Klein H, et al. [Pacing therapies for congestive heart failure considering the results of the PATH-CHF study]. [German]. Zeitschrift fur Kardiologie. 2001;90(Suppl 1):10-15. [pmid: 11261333].
136 Stellbrink C, Breithardt O A, Franke A, et al. Impact of cardiac resynchronization therapy using hemodynamically optimized pacing on left ventricular remodeling in patients with congestive heart failure and ventricular conduction disturbances. J Am Coll Cardiol. 2001;38(7):1957-1965. [pmid: 11738300].
137 Vogt J, Krahnefeld O, Lamp B, et al. Electrocardiographic remodeling in patients paced for heart failure. Am J Cardiol. 2000;86(9 Suppl.1):152K-156K.
138 Pitt B, Zannad F, Remme W J, et al. The effect of spironolactone on morbidity and mortality in patients with severe heart failure. Randomized Aldactone Evaluation Study Investigators. N Engl J Med. 1999;341(10):709-717. [pmid: 10471456].
139 Auricchio A, Spinelli J C, Trautmann S I, et al. Effect of cardiac resynchronization therapy on ventricular remodeling. J Cardiac Fail. 2002;8(2):S549-S555.
140 Sinha A M, Filzmaier K, Breithardt O A, et al. Usefulness of brain natriuretic peptide release as a surrogate marker of the efficacy of long-term cardiac resynchronization therapy in patients with heart failure. Am J Cardiol. 2003;91(6):755-758. [pmid: 12633819].
141 Bradley D J, Bradley E A, Baughman K L, et al. Cardiac resynchronization and death from progressive heart failure: a meta-analysis of randomized controlled trials. JAMA. 2003;289(6):730-740. [pmid: 12585952].
142 Gregoratos G, Abrams J, Epstein A E, et al. ACC/AHA/NASPE 2002 guideline update for implantation of cardiac pacemakers and antiarrhythmia devices: summary article. A report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (ACC/AHA/NASPE Committee to Update the 1998 Pacemaker Guidelines). J Cardiovasc Electrophysiol. 2002;13(11):1183-1199. [pmid: 12475117].
143 Strickberger S A, Hummel J D, Bartlett T G, et al. Amiodarone versus implantable cardioverter-defibrillator:randomized trial in patients with nonischemicdilated cardiomyopathy and asymptomaticnonsustained ventricular tachycardia-AMIOVIRT. J Am Coll Cardiol. 2003;41(10):1707-1712. [pmid: 12767651].
144 Bansch D, Antz M, Boczor S, et al. Primary prevention of sudden cardiac death in idiopathic dilated cardiomyopathy: the Cardiomyopathy Trial (CAT). Circulation. 2002;105(12):1453-58. [pmid: 11914254].
145 Cohn J N, Tognoni G. the Valsartan Heart Failure Trial Investigators. A Randomized Trial of the Angiotensin-Receptor Blocker Valsartan in Chronic Heart Failure. N Engl J Med. 2001;345(23):1667-1675. [pmid: 11759645].
146 Hjalmarson A, Goldstein S, Fagerberg B, et al. Effects of controlled-release metoprolol on total mortality, hospitalizations, and well-being in patients with heart failure: The metoprolol CR/XL randomized intervention trial in congestive heart failure (MERIT-HF). JAMA. 2000;283(10):1295-1302. [pmid: 10714728].
147 Lee T H, Marcantonio E R, Mangione C M, et al. Derivation and prospective validation of a simple index for prediction of cardiac risk of major noncardiac surgery. Circulation. 1999;100(10):1043-1049. [pmid: 10477528].
148 Butter C, Auricchio A, Stellbrink C, et al. Effect of resynchronization therapy stimulation site on the systolic function of heart failure patients. Circulation. 2001;104(25):3026-3029. [pmid: 11748094].
149 Pappone C, Rosanio S, Oreto G, et al. Cardiac pacing in heart failure patients with left bundle branch block: Impact of pacing site for optimizing left ventricular resynchronization. Ital Heart J. 2000;1(7):464-469. [pmid: 10933328].
150 Pablos-Mendez A, Barr R G, Shea S. Run-in periods in randomized trials: implications for the application of results in clinical practice. JAMA. 1998;279(3):222-225. [pmid: 9438743].
151 MacLean C H, Morton S C, Ofman J J, et al. How useful are unpublished data from the Food and Drug Administration in meta-analysis?. J Clin Epidemiol. 2003;56(1):44-51. [pmid: 12589869].
152 McAuley L, Pham B, Tugwell P, et al. Does the inclusion of grey literature influence estimates of intervention effectiveness reported in meta-analyses?. Lancet. 2000;356(9237):1228-1231. [pmid: 11072941].
153 Maisel W H, Stevenson L W. A trial fibrillation in heart failure: epidemiology, pathophysiology, and rationale for therapy. Am J Cardiol. 2003;91(6A):2D-8D.
154 McAlister F A, Teo K K, Taher M, et al. Insights into the contemporary epidemiology and outpatient management of congestive heart failure. Am Heart J. 1999;138(1 Pt 1):87-94. [pmid: 10385769].
155 Drummond MF, O'Brien BJ, Stoddart GL, Torrance GW. Collection and analysis of data. In: Methods for the Economic Evaluation of Health Care Programs. 2d ed. Oxford: Oxford University Press; 1997, p232–264.
156 Mason J, Drummond M, Torrance G W. Some guidelines on the use of cost effectiveness league tables. BMJ. 1993;306(6877):570-572. [pmid: 8461776]. [pmcid: 1677169].
157 Bigger J T Jr. Prophylactic use of implanted cardiac defibrillators in patients at high risk for ventricular arrhythmias after coronary-artery bypass graft surgery. coronary artery bypass graft (CABG) Patch Trial Investigators. N Engl J Med. 1997;337(22):1569-1575. [pmid: 9371853].
158 Connolly S J, Hallstrom A P, Cappato R, et al. Meta-analysis of the implantable cardioverter defibrillator secondary prevention trials. AVID, CASH and CIDS studies. Antiarrhythmics vs Implantable Defibrillator study. Cardiac Arrest Study Hamburg. Canadian Implantable Defibrillator Study. Eur Heart J. 2000;21(24):2071-78. [pmid: 11102258].
159 Wilkoff B, Cook J R, Epstein A E, et al. Dual-chamber pacing or ventricular backup pacing in patients with an implantable defibrillator: the Dual Chamber and VVI Implantable Defibrillator (DAVID) Trial. JAMA. 2002;288(24):3115-3123. [pmid: 12495391].
160 De Sutter J, De Bondt P, Van de W C, et al. Prevalence of potential candidates for biventricular pacing among patients with known coronary artery disease: a prospective registry from a single center. Pacing Clin Electrophysiol. 2000;23(11 Pt 2):1718-1721. [pmid: 11139908].
161 Farwell D, Patel N R, Hall A, et al. How many people with heart failure are appropriate for biventricular resynchronization?. Eur Heart J. 2000;21(15):1246-1250. [pmid: 10924314].
162 Werling C, Weisse U, Siemon G, et al. Biventricular pacing in patients with ICD: how many patients are possible candidates?. Thorac Cardiovasc Surg. 2002;50(2):67-70. [pmid: 11981703].
163 Lozano I, Bocchiardo M, Achtelik M, et al. Impact of biventricular pacing on mortality in a randomized crossover study of patients with heart failure and ventricular arrhythmias. Pacing Clin Electrophysiol. 2000;23(11 Pt2):1711-12. [pmid: 11139906].