# Acknowledgments

We are grateful to members of the technical expert panel, Dr. Gerald Peden (Medical Director of Independent Blue Cross) and Ms Margaret Coopey (Agency for Healthcare Research and Quality), who provided direction for the scope and content of the review.

We would like to thank the peer-reviewers who provided valuable input into the draft report: Dr. Bruce Wilkoff (The Cleveland Clinic Foundation, Cleveland, OH), Dr. Donald Casey (Catholic Healthcare Partners, Cincinnati, Ohio), Dr. Robert Rea (Mayo Clinic, Rochester, MN), Dr. Robert Kowal (UT Southwestern Medical Center, Dallas, TX), Dr. Clyde Yancy (St. Paul University Hospital/UT Southwestern Medical Center, Dallas, TX), Dr. David Atkins (Center for Outcomes and Evidence Agency for Healthcare Research and Quality), Dr. Cynthia Mulrow, and Dr. Joanna E. Siegel (Research Initiative in Clinical Economics, Center for Outcomes and Evidence Agency for Healthcare Research and Quality).

We are also grateful to authors of included studies who provided additional data or clarification on study methods and results: Dr. S. Cazeau, Dr. C. Leclercq, Dr. M. Bristrow, and Dr. S. Garrigue.

We thank Ms. Ella Huszti and Mr. John Bridges for their assistance in completing the decision analysis.

Investigating authors acknowledge the following financial support: Dr. Brian Rowe is supported by the Canadian Institutes of Health Research (CIHR) as a Canada Research Chair in Emergency Airway Diseases (Ottawa, Canada). He is also supported by the Faculty of Medicine and Dentistry and the Capital Health Authority, Edmonton, Alberta. Dr. Justin Ezekowitz is supported by a CIHR Strategic Training Fellowship. Dr. Finlay McAlister is a Population Health Investigator supported by the Alberta Heritage Foundation for Medical Research and is a New Investigator of CIHR. Dr. Graham Nichol is supported by two awards—Recipient of Career Scientist Award from Ontario Ministry of Health, and Premier's Research Excellence Award (Ontario). Dr. William Abraham has received research grants and speaker honoraria from Medtronic and Guidant Corporation.