# Discussion

## Systematic Review

### Efficacy and Safety

When added to proven efficacious medical therapy, cardiac resynchronization therapy reduces risk of all-cause mortality by 25% in patients with symptomatic CHF who have prolonged QRS duration and reduced left ventricular ejection fraction. This relative survival benefit is similar to those reported for ACE inhibitors, beta-blockers, and aldosterone antagonists in recent trials.^30,^ ^31,^ ^109,^ ^138^ When added to optimal medical therapy, 27 patients need to successfully undergo CRT implantation to prevent one death. This reduction in all-cause mortality occurs in both the sickest heart failure patients (those with NYHA Class III or IV symptoms) as well as those with milder disease (NYHA Class II symptoms), with identical relative benefits in both groups.

The survival benefits with cardiac resynchronization therapy become apparent by 3 months after implantation; [underlined: after the first 3 months], those patients receiving a biventricular pacemaker had 41% lower mortality risk than those without cardiac resynchronization therapy. It is likely that the benefits do not appear for several months because long-term benefits of cardiac resynchronization therapy are mediated through morphometric remodeling of the left ventricle rather than neurohormonal changes.^136,^ ^139^ Indeed, preliminary results have suggested that, while brain natriuretic peptide levels are reduced in patients by cardiac resynchronization,^94,^ ^140^ levels of norepinephrine, big endothelin, and other markers of inflammation are all unchanged. Thus, while drug therapies that impact both the neurohormonal system and ventricular remodeling in heart failure patients (such as ACE inhibitors and beta blockers) reduce the incidence of sudden cardiac death within weeks of being prescribed (possibly due to their immediate impact on the renin-angiotensin and sympathetic systems), several months are required for the benefits of cardiac resynchronization to become apparent and these benefits are largely restricted to progressive heart failure deaths.

Most of the survival benefits with cardiac resynchronization therapy appear to be attributable to a substantial reduction in the rate of progressive heart failure deaths (a 40% relative reduction), which is similar to the 51% relative risk reduction in progressive heart failure deaths found in a previous meta-analysis that incorporated four of the eight trials in this analysis.^141^ This is not surprising since the putative benefits of cardiac resynchronization therapy are via improved cardiac output, reduced mitral regurgitation, and reduced pulmonary capillary wedge pressure.^35,^ ^54,^ ^55^ While we found a non-significant trend toward increased sudden cardiac death that was consistent across these trials, that trend was based on a very small number of events (28 in total) and thus is not interpretable without further trial data (particularly given the well recognized difficulties in sub-classifying cardiac deaths as sudden or non-sudden). In particular, the lack of a difference in the number of ventricular arrhythmia episodes between those patients with, versus without, CRT in the MIRACLE ICD Trial (22% vs. 26%, p=0.47) suggests that the trend toward excess sudden cardiac deaths may well be due to small numbers.^94^

Regardless, the benefits of cardiac resynchronization therapy are similar in patients with or without implantable cardioverter defibrillators, providing some reassurance that, in those patients who have indications for both an ICD and a biventricular pacemaker, the two may be administered together. An issue that remains to be resolved by ongoing studies (and is beyond the scope of this systematic review) is the role of ICDs for primary prevention in patients with heart failure,^47^ which is particularly controversial in those patients with NYHA Class IV symptoms^142^ or with non-ischemic dilated cardiomyopathy.^143,^ ^144^ A large study, SCD-HeFT, which is due to report its findings in December 2003, should help clarify this isue.^84^ (http://www.sicr.org/scdheft/index.html accessed August 18, 2003)

Cardiac resynchronization therapy also led to a 32% reduction in hospitalizations for heart failure. This benefit was more marked in those heart failure patients who were more symptomatic and thus at higher risk for hospitalization (i.e., those with NYHA Class III or IV symptoms): a 35% relative risk reduction. The magnitude of this benefit is similar to those reported for ACE inhibitors, beta-blockers, and aldosterone antagonists.^29–32,^ ^34–36^

Cardiac resynchronization therapy also conferred statistically and clinically significant benefits in quality of life, peak oxygen capacity, ejection fraction, left ventricular volumes, distance walked in six minutes, and NYHA Class in patients with advanced heart failure and prolonged QRS duration. Quality of life is an important endpoint for heart failure, and a pooled six-point improvement on the Minnesota Living With Heart Failure instrument is larger than that seen in other heart failure trials and is greater than the minimal clinically important difference of 5 reported by the developers of the scale.^109–111,^ ^145,^ ^146^

An important finding of this systematic review is the safety of cardiac resynchronization therapy and its tolerability in patients with advanced heart failure. Peri-implantation mortality rates were less than 1%, despite the increased peri-operative mortality risk many of these patients face secondary to their heart failure, age, and frequent comorbidities such as renal failure and diabetes mellitus.^147^ Post-implantation infection rates were also low (approximately 1%). However, although there were few serious complications, implantation of a biventricular pacemaker (in particular the left ventricular [LV] lead) is technically challenging, even in experienced hands. Our systematic review identified a 10% failure rate for implantation of a biventricular pacemaker, largely due to problems positioning the LV lead. Furthermore, even if successfully implanted, these devices require close followup as 7% of devices malfunctioned over a median followup of six months, and 9% of LV leads dislodged. As such device failure complications will require another intervention and/or a new device to fix the problems, the failure rates have to be incorporated into any cost-effectiveness analyses for these devices. Further, the reductions in heart failure hospitalizations observed with CRT therapy may be offset to some degree by increased admissions for CRT revisions (although we were unable to obtain analyzable data on CRT revision admissions in these trials).

Location of the ventricular lead may be crucial to determining which patients respond best to therapy.^148,^ ^149^ However, although individual trials reported the final location of the implanted LV lead, outcomes and other information regarding location were not useable for pooled analysis as data were not stratified by final location of the LV lead. It is plausible, though, that current implantation success rates may be higher than those documented in these trials, as the experience of CRT device implanters, the tools for implantation, and the sophistication of the devices has improved over the past few years; however, ongoing surveillance is necessary to substantiate this.

### Potential Limitations of Systematic Review

A substantial limitation of the trials included in this analysis is that randomization occurred after implantation of the device in all but one trial. This design, similar to the run-in period in some pharmaceutical trials, does not affect the internal validity of the trials, but does impact the generalizability of the data because patients who could not tolerate the procedure or in whom implantation was unsuccessful were not included. As a result, these trials likely overestimate the potential benefits from cardiac resynchronization therapy.^150^ Thus, costing exercises based on our systematic review must take into account the up-front failure rates and peri-implantation mortality rates demonstrated in Table 14.

It deserves emphasis that only selected patients and experienced providers participated in these trials; while this also does not affect the internal validity of the trials, it again impacts the generalizability of the results. In particular, the observed implant success rates and complication rates may not be achievable in other settings with clinicians less experienced with device implantation.

Our analysis incorporated publicly available information from the web site of the FDA; this information, although not in the peer-review literature, is valid information for use in a systematic review.^151^ Indeed, a recent meta-analysis of non-steroidal anti-inflammatory agents has demonstrated that there is little difference in methodological quality between peer-reviewed published reports and the publicly available FDA reports.^151^ We subjected this and other unpublished literature to the same rigorous assessment of quality as we used for the published literature. Two of the trials that we incorporated into this review were available directly from the FDA and represent over 1,000 patients; we supplemented this information with data from the primary investigators and other sources to ensure its validity. One of these trials (n=227) did not find any differences in survival or hospitalization (but did find “positive” effects on functional outcomes and quality of life scores) and remains unpublished more than two years since final data was presented. (CONTAK CD^73^ was presented in May 2001 at the North American Society for Pacing and Electrophysiology 2001.) Exclusion of this trial exaggerates the benefit of cardiac resynchronization on all-cause mortality, a common finding amongst meta-analyses that exclude unpublished literature.^152^

Finally, very few patients in these trials had bradyarrhythmias, which would have necessitated conventional pacemakers, or atrial fibrillation. The role of cardiac resynchronization therapy in such patients is unknown and is an important area for further study (particularly since almost one third of CHF patients have atrial fibrillation or indications for a conventional pacemaker).^97,^ ^153,^ ^154^

## Decision Analysis

Our analysis shows that CRT plus medical therapy compared to medical therapy alone for patients with symptomatic heart failure is associated with a median incremental cost per quality-adjusted life year which is similar to that of other common medical interventions;^15^ however, there is a large degree of uncertainty in these incremental costs per quality-adjusted life year. The results were sensitive to the value of several key variables, including the effectiveness of CRT, the probability of cardiovascular death without pacing, and the incidence of device-related adverse effects.

The results of this analysis should be interpreted cautiously given the magnitude of the uncertainty in results. An intervention that is consistently more effective and less costly than its comparator is considered to be strongly dominant and always preferred to the alternative.^155^ In the current example, cardiac resynchronization is likely more costly and more effective than medical therapy (i.e. in right upper quadrant of Figure 14). If CRT is as efficacious and inexpensive as demonstrated in this study, it may be good value for money. The challenge will be to ensure that CRT is used in patients who meet these trials' inclusion criteria, and that CRT devices are inserted by experienced providers who have low complication rates. [underlined: However, the uncertainty about the benefits beyond one year needs to be acknowledged and there is insufficient long-term effectiveness and cost data to warrant broad implementation of CRT at this time].

This analysis has several strengths. It used currently recommended methods of economic evaluation.^78^ The effectiveness estimates incorporated into the decision analysis were based on a high-quality systematic review. Long-term effects and costs were considered from a health care system perspective. Finally, the analysis was based on the framework of a previously published economic analysis^83^ to facilitate comparison of the economics of different interventions in patients with cardiovascular disease.

### Potential Limitations of Decision Analysis

This analysis has several limitations. First, CRT had a different pooled effect on all cause mortality versus cardiac mortality. These variable effects may reflect differences in the duration of followup since the former analysis was based on longer-term followup than the latter one. Conversely, the analysis of cardiac death is susceptible to bias since it is difficult to assign cause of death in cardiovascular trials. However, in a separate but related patient population, implantable defibrillator insertion was associated with increased early mortality.^157^ Although the pooled effect of implantable defibrillators in patients at risk of sudden death is beneficial,^47,^ ^158^ use of a combined implantable defibrillator and biventricular pacemaker will not necessarily decrease mortality.^159^ Since patients with heart failure experience lethal bradyarrhythmia and tachyarrhythmias, a large randomized trial is evaluating the effect of devices with implantable defibrillator and biventricular pacemaking capability. (Personal communication, Dr. ASL Tang, August 25, 2003.)

Second, only selected implant physicians participated in the randomized trials assessing the effectiveness of CRT. It is plausible that the experience observed with the selected cases and experienced providers in these trials may not apply to other settings. If so, our analysis overestimates survival and underestimates the incremental cost of CRT in patients with heart failure. Conversely, if adverse effects are less frequent as providers gain experience, our analysis underestimates survival and overestimates the incremental cost of CRT in patients with heart failure. This is particularly important since the results of our analysis were sensitive to the rate of complications associated with CRT.

Third, the incidence of complications associated with CRT likely decreases over time while our analysis assumed that they were constant. If so, then our model underestimates survival and overestimates the incremental cost-effectiveness of CRT. Long-term followup of patients enrolled in the previously completed trials will determine whether the incidence of complications does indeed decline over time.

Fourth, it is likely that CRT may be associated with significant improvements in health-related quality of life relative to medical therapy. These trials demonstrated statistically significant differences in six-minute walk distance, functional class, and quality of life. Assuming that such short-term benefits persisted would have biased our results in favor of the intervention. Instead, the primary analysis assumed no difference in quality of life. Secondary analyses demonstrated that if resynchronization is associated with long-term improvements in quality of life, then it is even better value compared to medical therapy.

Fifth, it is unlikely that the relative benefit of CRT will be constant as the severity of heart failure increases. Therefore, as results from trials of CRT become available, our analysis should be revised to reflect better estimates of the true effectiveness and costs of the program.

Sixth, the model did not consider short- or long-term benefits and costs of selected surgical interventions for patients with heart failure. For example, cardiac transplantation is widely available but is infrequently used due to supply constraints and is associated with multiple long-term complications that were outside the scope of our analysis. Similarly, ventricular assist devices increase survival and quality of life, but are associated with frequent side effects and large costs.^44^ Surgical remodeling is currently being evaluated in a large National Institutes of Health-sponsored trial. None of these interventions have been demonstrated to be effective in patients with moderate (NYHA Class II and III) heart failure similar to those composing the bulk of patients in the CRT trials.

Seventh, we assumed that heart failure costs were constant even though implementation of CRT will decrease heart failure costs if any associated ventricular remodeling decreases the frequency of use of outpatient pharmaceuticals or duration of hospitalization.

Finally, the input data were derived from several sources and may be confounded by information that was not incorporated into the model. For example, the effectiveness of CRT was not adjusted for the patient's comorbid illnesses. Until additional data are available on the long-term effectiveness and costs of CRT, device implantation should be limited to patients who meet the inclusion criteria of the trials in the absence of comorbid illness. Such device implantation should only be performed by experienced providers.

## Conclusions

We have demonstrated a 24% relative reduction in [underlined: all-cause mortality] (largely driven by a 40% relative reduction in [underlined: progressive heart failure deaths]) and a 35% relative reduction in [underlined: CHF hospitalizations] with cardiac resynchronization therapy in patients with reduced ejection fractions, NYHA class III or IV symptoms despite currently accepted medical management (ACE inhibitors, beta-blockers, and in many cases digoxin and/or spironolactone), and a prolonged QRS duration on electrocardiogram. Successful implantation of a CRT device in 24 such patients would prevent one death and two heart failure hospitalizations.

We also found statistically and clinically significant improvements in quality of life and functional outcomes in patients receiving cardiac resynchronization therapy.

Up to 10% of CHF patients have reduced ejection fraction, NYHA Class III or IV symptoms, and a prolonged QRS duration; half of them would also have indications for an implantable cardioverter defibrillator.^142,^ ^160–162^ Thus, approximately 250,000 Americans may be eligible for a biventricular pacemaker and another 250,000 for a combined biventricular pacemaker/ICD.

While preliminary data suggest similar relative benefits (but lower absolute benefits) in patients with NYHA Class II symptoms, the role of cardiac resynchronization therapy in lower risk CHF patients with prolonged QRS duration is untested; further data are required before extending the device indications beyond those authorized by the FDA (i.e., patients with NYHA class III or IV symptoms). As very few such patients were enrolled in the trials, the role of cardiac resynchronization therapy in patients with either (1) indications for conventional pacemakers or (2) atrial fibrillation are unknown at this time and require further study.

However, some considerations need to be incorporated into any policy decisions about cardiac resynchronization therapy. First, although cardiac resynchronization appears to be relatively safe, there is a 10% failure rate for implantation; another 9% of patients may require the system to be partially or fully changed within six months due to malfunctions or lead displacements. As the technology develops, it is likely that the rates of implant failure and post-procedure complications will decrease (although close post-marketing surveillance is required to confirm this). Second, a marked paucity of data exists for the efficacy and complication rates with CRT devices beyond one year. Finally, none of these trials reported admission rates for CRT revisions; it is possible that much of the benefit in reduced heart failure hospitalization may well be offset by such admissions

Although the long-term cost-effectiveness of cardiac resynchronization therapy remains uncertain at this time (pending further data on longer term complication rates and benefits), our analyses do demonstrate that the incremental cost-effectiveness ratio is similar to other commonly used interventions, but has wide uncertainty and is sensitive to multiple inputs. There is insufficient long-term effectiveness and cost data to determine whether CRT is sufficient value for money to warrant its broad implementation at this time. We believe that, in light of the current evidence base, CRT should be reserved for selected heart failure patients with advanced disease (NYHA Class III or IV despite optimal medical therapy, reduced ejection fraction, and prolonged QRS duration—see Figure 16 for management algorithm), should only be implanted by clinicians competent in the technique, and should include close followup for complications.

Figure 16. Analytic framework for treatment options for patients with congestive heart failure