# Results

## Literature Search

Of more than 3000 initial references, only nine and 17 studies were accepted for the efficacy and safety reviews, respectively (Figure 3). Two of these were unpublished manuscripts describing studies that met the inclusion criteria. Another was a report submitted to the FDA on the MIRACLE^35^ trial to enhance data from the published trial results.^61^ Also included were the FDA reports on the MIRACLE ICD^93^ and CONTAK CD^73^ trials found on the FDA web site. (We used the published report for data on patients with NYHA Class III or IV symptoms in the MIRACLE ICD^94^ Trial, and the FDA report for NYHA Class II data since this was not included in the journal publication.) Bristow published the protocol for the COMPANION trial in 2000,^95^ and the results were presented at the Annual Scientific Conference of the American College of Cardiology in Chicago, April 2003. Further unpublished data from this trial were made available to us and are included in the analysis.

Figure 3. Flow diagram of study retrieval and selection for cardiac resynchronization therapy

There were three main reasons for exclusion of studies from the review: 1) the intervention studied was not CRT; 2) the article was a review, a protocol, or an editorial; and 3) the study did not report our outcomes of interest. The list of excluded studies and reasons for exclusion are identified at the end of the Reference List.

Most of the included trials were associated with multiple publications that either expanded on the main results or reported secondary outcomes not included in the primary report. We only included the primary report for each trial, but did extract data on secondary outcomes if they were reported only in these secondary publications. Table 4 (end of chapter) identifies the associated publications.

Table 4. Primary publications and associated publications of trials included in the reviews on cardiac resynchronization therapy in CHF

COMPANION Study
Primary report: ^60^ Bristow MR, et al. Comparison of medical therapy, pacing and defibrillation in heart failure. Presented at the 52nd Annual Scientific Conference, American College of Cardiology, Chicago, Illinois, USA, March 31st, 2003.
Other publications associated with COMPANION
^95^Bristow MR, Feldman AM, Saxon LA. Heart failure management using implantable devices for ventricular resynchronization: Comparison of medical therapy, pacing, and defibrillation in chronic heart failure (COMPANION) trial. J Card Fail 2000; 6(3):276–85
CONTAK CD Study
Primary report: ^73^GUIDANT Corporation, Cardiac Rhythm Management. Summary of safety and effectiveness: Guidant CONTAK CD CRT-D system including the CONTACK CD CRT-D pulse generator model 1823, and software application model 2848. PMA: P010012. Food and Drug Administration July 10, 2002.
Other publications associated with CONTAK CD
^112^Boehmer JP, DeMarco T, Jaski BE, et al. Why ICD patients with heart failure (Class II–IV) are hospitalized: Do the reasons differ for patients who are treated with cardiac resynchronization therapy? [abst] J Am Coll Cardiol 2002;39(5):159A
^113^Higgins SL, Yong P, Sheck D, et al. Biventricular pacing diminishes the need for implantable cardioverter defibrillator therapy. Ventak CHF Investigators. J Am Coll Cardiol 2000;36(3):824–7
^163^Lozano I, Bocchiardo M, Achtelik M, et al. Impact of biventricular pacing on mortality in a randomized crossover study of patients with heart failure and ventricular arrhythmias. Pacing Clin Electrophysiol 2000;23(11Pt2):1711–12
^114^Saxon LA, Boehmer JP, Hummel J, et al. Biventricular pacing in patients with congestive heart failure: two prospective randomized trials. The VIGOR CHF and VENTAK CHF Investigators. Am J Cardiol 1999;83(5B):120–23D
^115^Saxon LA, De Marco T, Schafer J, et al. Effects of long-term biventricular stimulation for resynchronization on echocardiographic measures of remodeling. Circulation 2002;105(11):1304–10
INSYNC Study
Primary report: ^100^Gras D, Leclercq C, Tang AS, et al. Cardiac resynchronization therapy in advanced heart failure the multicenter InSync clinical study. Eur J Heart Fail 2002;4(3):311–20.
Other publications associated with InSync
^116^Gras D, Mabo P, Tang T, et al. Multisite pacing as a supplemental treatment of congestive heart failure: preliminary results of the Medtronic Inc. InSync Study. Pacing Clin Electrophysiol 1998;21(11 pt2):2249–55
^117^Gras D, Cazeau S, Ritter P, et al. Long term results of cardiac resynchronization for heart failure patients: The InSync Clinical Trial [abst] Circulation 1999;100(18):2714
^118^Gras D, Cazeau S, Mabo P, et al. Long-term benefit of cardiac resynchronization in heart failure patients: The 12 month results of the InSync trial. [abst] J Am Coll Cardiol 2000;35(2):230A.
^119^Gras D, Mabo P, Bucknall C, et al. Responders and nonresponders to cardiac resynchronization therapy: Results from the InSync trial. J Am Coll Cardiol 2000;35(2):230A–230A
^120^Tang ASL, Gras D, Mabo P, et al. Mortality and outcome differences between survivors and nonsurvivors in the InSync cardiac resynchronization trial [abst] Circulation 1999;100(18):2715
^121^Zardini M, Tritto M, Bargiggia G, et al. The InSync-Italian Registry: analysis of clinical outcome and considerations on the selection of candidates to left ventricular resynchronization. Eur Heart J Supp 2002;2:J16–22
Leclercq Studies
Primary report: ^96^Leclercq C, Victor F, Alonso C, et al. Comparative effects of permanent biventricular pacing for refractory heart failure in patients with stable sinus rhythm or chronic atrial fibrillation. Am J Cardiol 2000;85(9):1154–56. Am J Cardiol 2000;85:1154–56
Other publications associated with Leclercq study
^107^Leclercq C, Cazeau S, Ritter P, et al. A pilot experience with permanent biventricular pacing to treat advanced heart failure. Am Heart J 2000;140(6): 862–70
MIRACLE Study
Primary report: ^61^Abraham WT, Fisher WG, Smith AL, et al. Cardiac resynchronization in chronic heart failure. N Engl J Med 2002;346(24):1845–1853
Other publications associated with the MIRACLE study
^122^Abraham WT. Rationale and design of a randomized clinical trial to assess the safety and efficacy of cardiac resynchronization therapy in patients with advanced heart failure: The Multicenter InSync Randomized Clinical Evaluation (MIRACLE). J Card Fail 2000;6(4):369–80
^123^Abraham WT, Fisher W, Smith A, et al. Cardiac resynchronization therapy reduces morbidity in patients with moderate to severe systolic heart failure and intraventricular conduction delays [abst]. J Am Coll Cardiol 2002;39(5):171A
^124^Abraham WT, Fisher W, Smith A, et al. Long-term improvement in functional status, quality of life and exercise capacity with cardiac resynchronization therapy: The MIRACLE Trial experience [abst]. J Am Coll Cardiol 2002;39(5):171A
^125^Aranda JM, Curtis AB, Conti JB, et al. Rationale and design of a randomized clinical trial to assess the safety and efficacy of cardiac resynchronization therapy in patients with advanced heart failure: The Multicenter InSync Randomized Clinical Evaluation (MIRACLE) [abst]. J Am Coll Cardiol 2002;39(5):96A
^126^Packer M & Abraham WT. Effect of cardiac resynchronization on a composite clinical status endpoint in patients with chronic heart failure: Results of the MIRACLE trial [abst]. Circulation 2001;104(17):1995
^127^Sutton MGS, Plappert T, Abraham WT, et al. Cardiac resynchronization improves diastolic ventricular function in advanced heart failure: The MIRACLE trial [abst]. Circulation 2001;104(17):2920
^128^Wagoner LE, Zengel PW, Abraham WT, et al. Cardiac resynchronization therapy with the InSync stimulation system improves exercise performance in patients with heart failure: MIRACLE trial substudy results [abst]. Circulation 2001;104(17):2919
MIRACLE-ICD study
Primary report: ^36^Medtronic, Inc. Summary of Safety and Effectiveness: InSync ICD Model 7272 dual chamber implantable cardioverter defibrillator with biventricular pacing for cardiac resynchronization, Attain Models 2187, 2188, 4189 leads. PMA: P010031. Food and Drug Administration, Dec 3, 2001
Other publications associated with MIRACLE ICD
^93^Medtronic, Inc. Summary of Safety and Effectiveness: InSync ICD Model 7272 dual chamber implantable cardioverter defibrillator with cardiac resynchronization therapy and the model 9969 Application Software. PMA: P010031. Food and Drug Administration, March 5, 2002
^94^Young JB, Abraham WT, Smith AL, et al. Combined cardiac resynchronization and implantable cardioversion defibrillation in advanced chronic heart failure The MIRACLE ICD Trial. JAMA 2003;289(20):2685–94
MUSTIC AF study
Primary report: ^75^Leclercq C, Walker S, Linde C, et al. Comparative effects of permanent biventricular and right-univentricular pacing in heart failure patients with chronic atrial fibrillation. Eur Heart J 2002;1780–87
MUSTIC SR study
Primary report: ^74^Cazeau S, Leclercq C, Lavergne T, et al. Effects of multisite biventricular pacing in patients with heart failure and intraventricular conduction delay. N Engl J Med 2001;344(12):873–80
Other publications associated with MUSTIC trials
^129^Linde C, Leclercq C, Rex S, et al. Long-term benefits of biventricular pacing in congestive heart failure: results from the MUltisite STimulation in cardiomyopathy (MUSTIC) study. J Am Coll Cardiol 2002;40(1):111–18
PATH CHF study
Primary report: ^62^Auricchio A, Stellbrink C, Sack S, et al. Long-term clinical effect of hemodynamically optimized cardiac resynchronization therapy in patients with heart failure and ventricular conduction delay. J Am Coll Cardiol 2002;39(12):2026–33
Other publications associated with PATH-CHF
^53^Auricchio A, Stellbrink C, Sack S, et al. The Pacing Therapies for Congestive Heart Failure (PATH-CHF) study: rationale, design, and endpoints of a prospective randomized multicenter study. Am J Cardiol 1999;83(5B):130D
^130^Auricchio A, Klein H, Spinelli J. Pacing for heart failure: selection of patients, techniques and benefits. Eur J Heart Fail 1999;1(3);275–79
^53^Auricchio A, Stellbrink C, Block M, et al. Effect of pacing chamber and atrioventricular delay on acute systolic function of paced patients with congestive heart failure. Circulation 1999;99(23):2993–3001
^131^Auricchio A, Ding J, Spinelli JC, et al. Cardiac resynchronization therapy restores optimal atrioventricular mechanical timing in heart failure patients with ventricular conduction delay. J Am Coll Cardil 2002;39(7):1163–69
^132^Baumann LS, Kadhiresan VA, Yu Y, et al. Optimization of cardiac resynchronization therapy in heart failure patients by measuring transient cycle length changes [abst]. Eur Heart J 2001;22:443
^148^Butter C, Auricchio A, Stellbrink C, et al. Effect of resynchronization therapy stimulation site on the systolic function of heart failure patients. Circulation 2001;104(25):3026–29
^133^Cuesta F, Sack S, Auricchio A, et al. Long-term benefit of cardiac resynchronization therapy in heart failure patients: results of the PATH-CHF study. Eur Heart J 2001;22:130
^134^Cuesta F, Stellbrink C, Auricchio A, et al. Cardiac resynchronization therapy reduces heart failure hospitalization in the PATH-CHF study [abst]. Eur Heart J 2001;22:441
^135^Huth C, Friedl A, Klein H, Auricchio A. Pacing therapies for congestive heart failure considering the results of the PATH-CHF study] Zeitschrift fur Kardiologie 2001; 90 (Supp 1):10–15
^136^Stellbrink C, Auricchio A, Butter C, et al. Pacing therapies in congestive heart failure II study. Am J Cardiol 2000;86 (9 Supp 1):138K
^136^Stellbrink C, Breithardt OA, Franke A, et al. Impact of cardiac resynchronization therapy using hemodynamically optimized pacing on left ventricular remodeling in patients with congestive heart failure and ventricular conduction disturbances. Am J Cardiol 2001;38(7):1957–65
^137^Vogt J, Krahnefeld O, Lamp B, et al. Electrocardiographic remodeling in patients paced for heart failure. Am J Cardiol 2000;86(Supp 1):152–56K

## Efficacy Review

### Description of Included Studies

Nine randomized trials met the inclusion criteria for the efficacy review:

Abraham 2002: Multicenter InSync Randomized Clinical Evaluation (MIRACLE trial).^61^

Auricchio 2002: Pacing Therapies for Congestive Heart Failure (PATH CHF trial).^62^

Bristow 2003: Comparison of Medical Therapy, Pacing, and Defibrillation in Chronic Heart Failure (COMPANION trial).^60^

Cazeau 2001: Multisite Stimulation in Cardiomyopathies Sinus Rhythm (MUSTIC SR trial).^74^

Garrigue et al.^70^

Guidant Corporation: the CONTAK CD trial.^73^

Medtronic 2001: Multicenter InSync Randomized Clinical Evaluation ICD (MIRACLE ICD).^36,^ ^93,^ ^94^

Leclercq 2000: Multisite Stimulation in Cardiomyopathies Atrial Fibrillation (MUSTIC AF trial).^96^

RD-CHF: presented at the 2003 European Society of Cardiology Meeting and personal communication from Dr. C. Leclerq November, 2003.

Six of these trials have been published, (Garrigue et al., MIRACLE, MIRACLE ICD, MUSTIC AF, MUSTIC SR, and PATH CHF) and three (COMPANION, CONTAK CD, RD-CHF) were located from other sources as mentioned above. The four largest trials were conducted in North America,^36,^ ^60,^ ^61,^ ^73^ and the other five were conducted in the European Community.^62,^ ^70,^ ^74,^ ^75,^ ^RD-CHF^ Characteristics of the trials are summarized in Table 5 (end of chapter).

Table 5. Description of studies included in the efficacy review: CRT for CHF

| | | | Number of Participants
Study name | Country | Design | Control arm | Total enrolled | Exclusions | Total randomized | Treatment* | Control* | Withdrawals | Device | Authors' primary outcome(s) | Other outcomes
| | Duration | | | | | | | | Method of implant
Abraham 2002 MIRACLE^61^ | U.S. and Canada | RCT parallel | Pacer “Inactive” | 571 | 4 | 453 | 228 | 225 | Treatment 1 | InSync model 8040 Medtronic | NYHA class; QOL, 6MWT | Peak O_2_ consumption; time on a treadmill; LVEF; LVEDD; severity of mitral regurgitation; duration of QRS interval; clinical composite response (improved, worsened, unchanged); death; worsening heart failure; number of days spent in hospital
| | 6 mo. | | | | | | | Control 8 | Transvenous
Auricchio 2002 PATH-CHF^62^ | Germany, Netherlands | RCT X-over | Uni-ventricular pacing (4 right, 36 left) | 42 | 1 | 41 | 24 | 17 | Treatment 2 | Vigor / Discovery with LV lead Guidant | O_2_ uptake at peak exercise; O_2_ uptake at anaerobic threshold; 6MWT | NYHA; QOL
| | 1 mo. | | | | | | | Control 5 | Transthoracic
Bristow 2003 COMPANION^60^ | U.S. multicenter | RCT parallel 3 arms | OPT | - | - | 1520 | CRT=617 | 308 | - | CONTAK TR Models 4510–4513, Model 1241 CONTAK CD Model 1823 Guidant. | CRT: all-cause mortality & hospitalization. CRT-ICD: all-cause mortality & hospitalization | Cardiac morbidity; ADRs, implant success; peak O_2_ uptake at exercise
| | 12 mo. | | | | | CRT-D=595 | | | Transvenous
Cazeau 2001^74^ MUSTIC-SR | Europe (15 sites) | RCT X-over | Pacer “Inactive” | 67 | 3 | 58 | 29 | 29 | Treatment 4 | Chorum 7336 ELA Medical or InSync 8040 Medtronic | 6MWT | QOL (main secondary outcome); peak O_2_ uptake; hospital admissions because of decompensated heart failure; patient's preference with regard to pacing (active vs. inactive) at the end of crossover; death
| | 3 mo. | | | | | | | Control 3 | Transvenous
Garrigue 2002^70^ | France | RCT X-over | Left ventricular pacing | - | 0 | 13 | 6 | 7 | 0 | Model 2188 Medtronic | Clinical and hemodynamic variables | Hemodynamic changes during exercise
| | 2 mo. | | | | | | | | Transvenous
Guidant 2002 CONTAK-CD^73^ FDA Report | U.S. (47 sites) | RCT | Pacer “Inactive” | 581 | 15 | 490 | 245 | 245 | Treatment 3 | CONTAK-CD | All-cause mortality; CHF hospitalizations; ventricular tachyarrhythmia requiring device intervention | Peak O_2_ consumption; QOL; 6MWT, all adverse events
| | Phase I period 1 of X-over 3 mo | | | | | | | Control 1 | Transvenous and Transthoracic
| | Phase II parallel 6 mo.
Leclercq 2002 MUSTIC-AF^75^ | Europe (15 sites) | RCT X-over | Right ventricular pacing | 64 | 10 | 43 | 25 | 18 | Treatment 1 | ELA medical, Medtronic | 6MWT | Peak O_2_ consumption; QOL; hospital admissions for decompensated heart failure; mortality; patient's preferred period at end of crossover
| | 3 mo. | | | | | | | Control 2 | Transvenous
| | | | | | | | | Both 2
Leclercq 2003 RD-CHF** Unpublished | France | RCT X-over | Right ventricular pacing | 56 | Unclear | 44 | 22 | 22 | Unclear | Transvenous | CHF hospitalization | N/a
| | 3 mo.
Medtronic 2001 MIRACLE-ICD^36^ FDA report | U.S. and Canada (53 sites) | RCT (post implant) parallel | Pacer “Inactive” | 659 | 105 | 554 | 272 | 282 | Treatment 7 | Model 7272 InSync ICD, Attain LV leads models 4189, 2187, 2188. | NYHA; QOL; 6MWT; | ADRs; QRS; peak O_2_ uptake; echocardiographic indices; LV lead electrical performance; VT/VF therapy; CHF composite response; implant ventricular defibrillation criterion; ATP therapy; healthcare utilization; death
| | 6 mo. | | | | | | | Control 6 | Transvenous

ADR = adverse reaction; CRT = cardiac resynchronization therapy; CRT ICD = CRT with implanted cardioverter defibrillator; FDA = Food and Drug Administration; LVEF = left ventricular ejection fraction; LVEDD = left ventricular end diastolic diameter; N/a = not available; NYHA = New York Heart Association class; QOL = quality of life; OPT = optimal pharmacological therapy; RCT = randomized control trial; 6MWT = 6-minute walk test; X-over = crossover study

* the intervention that crossover studies received in the first period

** detailed data not available for Leclercq 2003 (RD-CHF) at the time this report was prepared

t excludes deaths and implant failures, where applicable

Note: While the published report for MIRACLE-ICD was used for patients with NYHA Class III or IV symptoms, the FDA report was used for NYHA Class II patients as they were not included in the published MIRACLE-ICD manuscript

In total, 3574 patients were enrolled in these trials and 3216 (90%) were randomized to receive CRT (n=2063) or control (n=1153). The majority of those who were enrolled but not randomized had failed implant attempts. The mean age of enrolled patients was 64 ± 3 years and 74% were male. Approximately 75% were considered NYHA class III (range 55% to 100%) and 10% NYHA class IV (range 6% to33%). Two trials included NYHA class II (range 10% to 38%).^36,^ ^73^ Ethnic background was available from one trial in which 90% were Caucasian.^61^ Further details about baseline characteristics for each trial are presented in Table 6.

Table 6. Baseline characteristics of patients in trials included in the efficacy review: CRT for CHF

| | | | | NYHA class | | | | ECG | | | Physical exam | | | Other co-morbidities
| | | | | II | III | IV | Atrial fibrillation | PR interval | QRS interval | LVEDD | Systolic BP | Diastolic BP | HR
Trial name | Study Group | Males n (%) | Age mean SD | Ischemic % | % | % | % | n (%) | mean SD (msec) | mean SD (msec) | mean SD (mm) | mean SD | mean SD | mean SD | LBBB % | LVEF %
Abraham 2002^61^ MIRACLE | CRT | 155 (68) | 64 +/- 11 | 50 | - | 90 | 110 | 0 | - | 167 +/- 21 | 70 +/- 10 | 114 +/- 18 | 69 +/- 10 | 73 +/- 13 | - | 22 +/- 6
| Control | 153 (68) | 65 +/- 11 | 58 | - | 91 | 9 | 0 | - | 165 +/- 20 | 69 +/- 10 | 115 +/- 18 | 68 +/- 10 | 75 +/- 13 | - | 22 +/- 6
Auricchio 2002 PATH-CHF^62^ | CRT first | 11 (46) | 59 +/- 7 | 42 | - | 88 | 13 | 0 | 190 +/- 34 | 174 +/- 30 | 71 +/- 10 | - | - | 77 +/- 16 | 88 | 21 +/- 6
| Control first | 10 (59) | 60 +/- 5 | 6 | - | 82 | 18 | 0 | 207 +/- 30 | 178 +/- 34 | 75 +/- 13 | - | - | 80 +/- 13 | 100 | 20 +/- 7
| All | 21 (50) | 60 +/- 7 | 29 | - | 86 | 14 | 0 | 196 +/- 33 | 175 +/- 32 | 73 +/- 11 | - | - | 78 +/- 15 | 93 | 21 +/- 7
Bristow 2003^60^ COMPANION | CRT | 413 (67) | 65 | 54 | - | 87 | 13 | 0 | - | 159 | - | - | - | - | 69 | 22
| Control | 213 (69) | 67 | 59 | - | 82 | 18 | 0 | - | 156 | - | - | - | - | 70 | 23
| CRT-ICD | 399 (67) | 66 | 55 | - | 86 | 14 | 0 | - | 159 | - | - | - | - | 73 | 23
Cazeau 2001^74^ MUSTIC-SR | CRT first | 19 (66) | 64 +/- 11 | - | - | 100 | | 0 | - | 172 +/- 22 | - | - | - | - | - | -
| Control first | 24 (83) | 64 +/- 8 | - | - | 100 | | 0 | - | 175 +/- 19 | - | - | - | - | - | -
| All | 43 (74) | 64 +/- 9 | 37 | - | 100 | | 0 | 215 +/- 43 | 174 +/- 20 | 73 +/- 10 | - | - | - | - | 23 +/- 7
Garrigue 2002^70^ | All | 13 (100) | 64 +/- 12 | 46 | - | 77 | 33 | 100 | - | 208+/- 15 | - | - | - | - | 62 | 25 +/- 8
Guidant 2002^73^ CONTAK-CD FDA report | CRT II–IV | 210 (85) | 66 +/- 11 | 67 | 32 | 60 | 8 | 0 | 205 +/- 42 | 160 +/- 27 | - | 118 +/- 21 | 67 +/- 12 | 73 +/- 12 | 54 | 21 +/- 7
| Control II–IV | 211 (83) | 66 +/- 11 | 70 | 33 | 57 | 10 | 0 | 202 +/- 49 | 156 +/- 26 | - | 118 +/- 21 | 69 +/- 12 | 75 +/- 14 | 55 | 22 +/- 7
| CRT III/IV | 90 (77) | 66 +/- 11 | 65 | 17* | 73 | 10 | 0 | 204 +/- 41 | 164 +/- 27 | - | 116 +/- 20 | 68 +/- 12 | 75 +/- 13 | 50 | 21 +/-6
| Control III/IV | 86 (78) | 66 +/- 11 | 71 | 10* | 71 | 19 | 0 | 200 +/- 54 | 152 +/- 24 | - | 117 +/- 23 | 67 +/- 14 | 74 +/-15 | 54 | 21 +/- 6
Leclercq 2002^74^ MUSTIC-AF | CRT first | 21 (84) | 65 +/- 9 | - | | 100 | | 25 (100) | - | 209 +/- 21 | 70 +/- 9 | - | - | 75 +/- 6 | - | 23 +/- 7
| Control first | 14 (78) | 66 +/- 9 | - | | 100 | | 18 (100) | - | 208 +/- 12 | 66 +/- 7 | - | - | 74 +/- 5 | - | 30 +/- 12
| All | 35 (81) | 65 +/- 8 | 43 | | 100 | | 43 (100) | - | 209 +/- 18 | 68 +/- 8 | - | - | 74 +/- 5 | - | 26 +/- 10
Leclercq 2003 RD-CHF** Unpublished | N/a | N/a | 73 +/- 8 | N/a | 0 | N/a | N/a | 23 (52) | N/a | N/a | N/a | N/a | N/a | N/a | N/a | 25 +/-/9
Medtronic 2001^36^ MIRACLE-ICD FDA report | CRT II–IV | 231 (82) | 66 +/- 12 | 38 | 32 | 60 | 8 | 16 (6) | - | 166 +/- 23 | 71 +/- 9 | 113 +/- 19 | 67 +/- 11 | 73 +/- 13 | 0.7 | 21 +/- 7
| Control II–IV | 217 (80) | 66 +/- 11 | 32 | 38 | 55 | 7 | 12 (4) | - | 163 +/- 22 | 70 +/- 9 | 113 +/- 17 | 68 +/- 12 | 73 +/- 13 | 0 | 21 +/- 7
| CRT III/IV | 142 (76) | 67 +/- 11 | 64 | | 88 | 12 | 49 (26) | - | 165 +/- 22 | 70 +/- 9 | - | - | 71 +/- 12 | 75 | 21 +/- 7
| Control III/IV | 136 (77) | 68 +/- 9 | 75 | | 89 | 11 | 31 (18) | - | 162 +/ -22 | 71 +/- 9 | - | - | 72 +/- 13 | 71 | 20 +/- 6

CRT = cardiac resynchronization therapy; FDA = Food and Drug Administration; HR = heart rate; LVEDD = left ventricular end diastolic diameter; LVEF = left ventricular ejection fraction; LBBB = left bundle branch block; N/a = not available; NYHA= New York Heart Association class

* pre-implant assessment

** detailed data not available for Leclercq 2003 (RD-CHF) at the time this report was prepared

Note: While the published report for MIRACLE-ICD was used for patients with NYHA Class III or IV symptoms, the FDA report was used for NYHA Class II patients as they were not included in the published MIRACLE-ICD manuscript

No trial specifically recruited patients based on the etiology of their heart failure, although patients with uncorrectable valvular disorders and hypertrophic or restrictive cardiomyopathy were excluded from all trials. In the three trials that evaluated CRT with ICDs, the majority of patients had ischemic etiology (~59%);^36,^ ^60,^ ^73^ in the other trials, ischemic etiology ranged from 37%^74^ to 55%.^61^ Other comorbidities such as diabetes mellitus, renal failure, previous cardiac history, or a history of sudden cardiac death were reported in only one trial.^93^

All trials (except PATH CHF, which did not specify an ejection fraction criteria)^62^ were limited to patients with an ejection fraction < 35% or < 40%. The mean ejection fractions were similar in all trials, and ranged from 21% to 30%. Six trials also specified a left ventricular end diastolic dimension: ≥ 55 mm in two trials^36,^ ^61^ and ≥ 60 mm in the other four trials.^60,^ ^70,^ ^74,^ ^75^ The reported mean left ventricular end diastolic dimension for the trials were similar (68 mm to 73 mm).

QRS width was a criteria for all trials, with three trials specifying ≥ 120 msec,^60,^ ^62,^ ^73^ two trials ≥ 130 msec,^36,^ ^61^ one trial >140 msec,^70^ one trial >150 msec,^74^ one trial >180 msec, and one trial >200 msec.^75^ Six of the nine trials had a mean QRS between 159 msec and 175 msec, with the MUSTIC AF trial having a mean QRS of 209 msec. Left bundle branch block was present in most patients (mean 64%; range 0 to100%).

Five trials were restricted to patients in normal sinus rhythm,^60,^ ^62,^ ^73,^ ^74^ but two were restricted to patients with atrial fibrillation^70,^ ^75^ In the eighth trial ~14% of patients had atrial fibrillation.^93^ Overall, approximately 5% of randomized patients included in this meta-analysis had atrial fibrillation. Three trials reported PR intervals that ranged from 196 msec to 215 msec and two required a prolonged PR interval >150 msec for inclusion.^60,^ ^62^ Three trials required a six-minute walk test result of less than 450 meters as an inclusion criterion.^61,^ ^74,^ ^75^ The physical exam findings at baseline were similar among trials, with systolic blood pressure (range 113 to 118 mmHg), diastolic blood pressure (range 67 to 69 mmHg), and heart rate (range 71 to 80 bpm) all similar to other trials in heart failure.^97^

In the three trials where implantable cardioverter defibrillators were tested along with cardiac resynchronization therapy,^36,^ ^60,^ ^73^ there was a general requirement that study patients meet indications for ICD placement. Although it was not specified by which ICD criteria patients were evaluated, the indications in MIRACLE ICD^36^ and CONTAK CD^73^ were consistent with the AHA/ACC/NASPE guidelines for secondary prevention. (Table C-1, available on the AHRQ web site, details the inclusion criteria of the individual trials.)

Medication use was specified in all but the PATH-CHF and RD-CHF trials.^62^ ACE inhibitors were required in all trials, beta-blockers were required in three,^60,^ ^61,^ ^70^ and spironolactone was only required in COMPANION.^60^ (Baseline medication use in the efficacy review trials is detailed in Table 7 at the end of this chapter.) Importantly, three European trials reported 31% use of amiodarone,^62,^ ^70,^ ^74^ and 38% of patients in the MIRACLE ICD trial were on non-beta-blocker anti-arrhythmic agents.^36^ Digoxin was used in 48% to 76% of patients, with the four largest trials having at least 75% of their patients on digoxin.^36,^ ^60,^ ^61,^ ^73^

Table 7. Baseline drug therapy for trials included in the efficacy review: CRT for CHF

| | Medications
Trial name | Study Groups | ACE % | ARB % | BB % | Spironolactone % | Digoxin % | Nitrates % | Others Name %
Abraham 2002^61^ MIRACLE | CRT | 93* | - | 62 | - | 78 | - | Diuretics (94)
| Control | 90* | - | 55 | - | 79 | - | Diuretics (93)
Auricchio 2002^62^ PATH-CHF | CRT | 96** | - | 71 | - | ** | 71 | Amiodarone (29)
| Control | 100** | - | 65 | - | ** | 71 | Amiodarone (35)
| All | 95** | - | 67 | - | ** | 69 | Amiodarone (30)
Bristow 2003^60^ COMPANION | CRT | 89* | * | 68 | 53 | - | - | Diuretics (100); digoxin (100)
| Control | 89* | * | 66 | 55 | - | -
| CRT-ICD | 90* | * | 68 | 55 | - | -
Cazeau 2001^74^ MUSTIC-SR | All | 96* | * | 28 | 22 | 48 | - | Amiodarone (31), diuretics (100)
Garrigue 2002^70^ | All | 100 | - | 100 | - | | - | Diuretics (100); amiodarone (100); CCB (100)
Guidant 2002^73^ CONTAK-CD FDA report | CRT, II–IV | 86* | * | 48 | - | 69 | - | Diuretics (88)
| Control, II–IV | 89* | * | 46 | - | 68 | - | Diuretics (83)
| CRT, III/IV | 81* | * | 45 | - | 72 | - | Diuretics (92)
| Control, III/IV | 89* | * | 40 | - | 68 | - | Diuretics (86)
Leclercq 2002^75^ MUSTIC-AF | All | 100* | * | 23 | 16 | 58 | - | -
Leclercq 2003 RD-CHF*** Unpublished | N/a | N/a | N/a | N/a | N/a | N/a | N/a | N/a
Medtronic 2001^36^ MIRACLE-ICD FDA report | CRT, II–IV | 93 | - | 63 | - | 71 | 31 | Diuretics (91); anti-depressant (16); CCB (6); antiarrhythmic (40); positive ionotrope (71); anti-coagulant (77).
| Control, II–IV | 90 | - | 59 | - | 72 | 30 | Diuretics (90); anti-depressant (17); CCB (6); anti-coagulant (79); antiarrhythmic (33); positive ionotrope (72)
| CRT, III/IV | 92 | - | 63 | - | 76 | 36 | Diuretics (93); anti-depressant (19); CCB (7); anti-coagulant(77); antiarrhythmic (42); positive ionotrope (76)
| Control, III/IV | 88 | 32 | 58 | - | 73 | 33 | Diuretics (94); anti-depressant (20); CCB (6); anti-coagulant (81); antiarrhythmic (32); positive ionotrope (73)

ACE= angiotensin converting enzyme inhibitors; ARB= angiotension-receptor blocks; BB= beta blocker; CCB= calcium channel blocker

* receiving angiotensin-converting-enzyme inhibitors or angiotension-receptor blockers

** receiving angiotensin-converting-enzyme inhibitors or digoxin

*** detailed data not available for Leclercq 2003 (RD-CHF) at the time this report was prepared

N/a =not available

Four of the trials employed a parallel study design.^36,^ ^60,^ ^61,^ ^73^ One of these had planned a crossover period but changed protocol mid-study and excluded crossover data from the analysis;^73^ five others completed a crossover design.^62,^ ^70,^ ^74,^ ^75,^ ^RD-CHF^ The duration of treatment was 4 weeks in PATH CHF,^62^ 2 months in Garrigue et al.,^70^ 3 months in RD-CHF, 3 months/phase in MUSTIC AF^75^ and MUSTIC SR,^74^ 6 months in MIRACLE^61^ and MIRACLE ICD,^36^ and 12 months in the COMPANION^60^ trial. Eight of the nine trials used a transvenous approach for placement of the epicardial leads (54 patients in CONTAK CD^73^ required a transthoracic approach), while PATH CHF^62^ used a transthoracic approach.

Parallel-arm trials. The MIRACLE trial^61^ enrolled 453 patients (NYHA Class III or IV); 228 were randomized to CRT ‘on’, 225 to CRT ‘off' (Table 5). The MIRACLE ICD trial^36^ enrolled 659 patients (NYHA Class II to IV; 434 in NYHA Class III/IV); 554 patients were randomized (364 in NYHA Class III/IV): 272 to CRT ‘on’ and 283 to CRT ‘off’. All patients in MIRACLE ICD^36^ received an implantable cardioverter defibrillator. For both MIRACLE^61^ and MIRACLE ICD,^36^ the primary outcomes were quality of life, six-minute walk test, and NYHA class.

COMPANION^60^ was a three-arm, parallel-group trial that compared optimal pharmacological therapy (n=308), cardiac resynchronization therapy (n=617), and cardiac resynchronization therapy with cardioverter defibrillator (n=595) randomized in a 1:2:2 fashion before device implantation. The primary outcome was a composite of all-cause mortality and all-cause hospitalization (including emergency room visits or unscheduled office visits requiring >4 hours of intravenous vasoactive or inotropic drug).

CONTAK CD^73^ was a two-part trial with an initial pilot crossover involving two 3-month phases (n=205 for first 3 month results). We were not able to obtain complete data from the second phase; hence this part of the trial was excluded from this report. For part two, they conducted a parallel design study with 6-month followup (n=151). The device used also had a cardioverter defibrillator. The primary outcome was a composite of all-cause mortality, heart failure hospitalizations, and ventricular arrhythmias requiring device intervention.

Crossover Trials. In MUSTIC SR,^74^ 67 patients were enrolled and implantation attempted, followed by an 8- to 12-week observation phase; 58 patients were then randomized into a 3-month crossover of either CRT ‘on’ or ‘off’ (Phase 1: n=29, Phase 2: n=29). In MUSTIC AF,^75^ 64 patients were enrolled and implantation attempted, followed by 8 to 12 weeks of observation; 43 were randomized into a 3-month crossover of CRT ‘on’ or ‘off’ (Phase 1: n=25, Phase 2: n=18). Both trials used the six-minute walk test as the primary outcome. Neither used a ‘washout’ period between phases and neither detected a carryover effect.

PATH CHF^62^ was a 4-week crossover study in which 42 patients were enrolled and implantation attempted; 41 patients were randomized to CRT 'on’ or ‘off’ in two phases with a 4-week washout period between the two (Phase 1: n=24, Phase 2: n=17). The primary endpoint was peak oxygen uptake on a maximal exercise test. This trial did detect a carryover effect.

Garrigue et al.^70^ used a 2-month crossover design in which 13 patients had the device implanted (plus HIS-bundle ablation). The 13 patients were randomized to either CRT or left-univentricular pacing alone. The primary endpoint was peak endocardial acceleration time as measured by an implantable sensor. Patients were crossed over after 2 months without a washout phase. The study did not assess for a carryover effect in the analysis.

### Methodological Quality of Included Studies

As a measure of methodological quality for the included trials, (end of chapter) the overall Jadad^58^ score (maximum five points) was 5 for one trial,^61^ 4 for three trials,^61,^ ^62,^ ^73^ 3 for three others,^60,^ ^74,^ ^75^ and one for the remaining study^70^ (Table 8). Insufficient details about the RD-CHF Trial were provided to be able to grade methodologic quality.

Table 8. Methodological quality of randomized trials included in the efficacy review

| Randomization | | Double-blinding
Study | Stated | Method described | Stated | Method described | Description of withdrawals/drop-outs | Jadad Score | Allocation Concealment
Abraham 2002 MIRACLE^61^ | Yes | Adequate | Yes | Adequate | Adequate | 5 | Clear
Auricchio 2000 PATH-CHF^62^ | Yes | Unclear | Yes | Adequate | Adequate | 4 | Unclear
Bristow 2003 COMPANION^60^ | Yes | Adequate | No | N/a | Unclear | 3 | Unclear
Cazeau 2001 MUSTIC-SR^74^ | Yes | Adequate | No | N/a | Adequate | 3 | Unclear
Garrigue 2002^70^ | Yes | Unclear | No | N/a | Unclear | 1 | Unclear
Guidant 2002 CONTAK-CD^73^ | Yes | Unclear | Yes | Adequate | Adequate | 4 | Unclear
Leclercq 2002 MUSTIC-AF^75^ | Yes | Adequate | No | N/a | Adequate | 3 | Unclear
Leclercq 2003 RD-CHF* (unpublished) | Yes | N/a | No | N/a | N/a | 1 | N/a
Medtronic 2001 MIRACLE-ICD^36^ | Yes | Unclear | Yes | Adequate | Adequate | 4 | Unclear

N/a = not available

* detailed data not available for Leclercq 2003 (RD-CHF) at the time this report was prepared

All trials were described as randomized; however, the description of randomization detail varied. As far as blinding, two were open-label,^60,^ ^70^ three were single-blind (i.e., the patient was blinded)^60,^ ^74,^ ^75^ and four were double-blind (patient and the outcome assessor was blinded).^36,^ ^61,^ ^62,^ ^73^ In CONTAK CD,^73^ MIRACLE,^61^ and MIRACLE ICD,^36^ the independent events committee was blinded to which arm of the trial the patient was in; no information was available for COMPANION.^60^ Notably, five trials randomized patients before implantation.^60,^ ^62,^ ^73–75^ An intention-to-treat statistical analysis was specified in all trials, and MIRACLE^61^ and PATH CHF^62^ performed an intention-to-treat analysis.^61,^ ^62^ In the remaining trials, it was either unclear^60,^ ^74,^ ^75^ or multiple analyses were done for the FDA that included an intention-to-treat analysis of all patients involved in the trial program^36,^ ^73^ Withdrawals and dropouts were clearly described in all trials except COMPANION.^60^ Unscheduled crossovers occurred in zero to nine percent of the patients in these trials and were generally balanced between study arms. Withdrawals ranged from zero to 3% for the cardiac resynchronization group and from zero to 2.5% for the control groups. Allocation concealment was unclear for all but the MIRACLE^61^ trial.

Industry sponsored seven of the nine trials; two also received funding from government sources.^74,^ ^75^ Guidant Corporation sponsored three,^60,^ ^62,^ ^73^ Medtronic Inc. sponsored four,^36,^ ^61,^ ^74,^ ^75^ and ELA Recherche funded two.^74,^ ^75^ Garrigue et al.^70^ did not report funding sources.

## Safety Review

### Description of Included Studies

Seventeen randomized (n=8) and cohort studies (n=9) met the inclusion criteria for the review of safety of cardiac resynchronization therapy (Table 9, end of chapter). Eight of the nine trials included in the efficacy review were eligible (Garrigue et al.^70^ did not contain any pertinent safety outcomes). The 9 additional studies included one randomized trial that did not report efficacy endpoints of interest^98^ and 8 prospective cohort studies,^70,^ ^96,^ ^99–103^ that included one unpublished manuscript submitted to us by an author of another included study.^104^ Thirteen studies reported that devices were implanted transvenously, two were transthoracic,^62,^ ^98^ and two used both approaches.^73,^ ^105^ Either Medtronic Inc. or Guidant Corporation manufactured all implanted devices; however, the models and leads varied among and within trials.

Table 9. Description of studies included in the safety review: CRT for CHF

| | | | Number of Participants
Study name | Country | Design | Control arm | Total enrolled | Exclusions^t^ | Total randomized | Treatment* | Control* | Withdrawals | Device | Authors' primary outcome(s) | Other outcomes
| | Duration | | | | | | | | Method of implant
Abraham 2002 MIRACLE^61^ | US. & Canada | RCT parallel | Pacer “Inactive” | 571 | -- | 453 | 228 | 225 | Treatment 1 | InSync model 8040 Medtronic | NYHA class; QOL, 6MWT | Peak O_2_ consumption; time on a treadmill; LVEF; LVEDD; severity of mitral regurgitation; duration of QRS interval; clinical composite response (improved, worsened, unchanged); death; worsening heart failure; number of days spent in hospital
| | 6 mo. | | | | | | | Control 8 | Transvenous
Auricchio 2002 PATH-CHF^62^ | Germany & Netherlands | RCT cross-over | Uni-ventricular pacing (4 Rt., 36 Lt.) | 42 | 1 | 41 | 24 | 17 | Treatment 2 | Vigor / Discovery with LV lead Guidant | O2 uptake at peak exercise; O2 uptake at anaerobic threshold; 6MWT | NYHA; QOL
| | 1 mo. | | | | | | | Control 5 | Transthoracic
Bristow 2003^60^ COMPANION | US. multicentre | RCT parallel 3 arms | OPT | - | - | 1520 | CRT=617 | 308 | - | CONTAK TR Models 4510–4513, Model 1241 CONTAK CD Model 1823 Guidant. | CRT: all-cause mortality & hospitalization. CRT-ICD: all-cause mortality & hospitalization | Cardiac morbidity; ADRs, implant success; peak O_2_ uptake at exercise
| | 12 mo. | | | | | CRT-D= 595 | | | Transvenous
Cazeau 2001^74^ MUSTIC-SR | Europe (15 sites) | RCT cross-over | Pacer “Inactive” | 67 | 3 | 58 | 29 | 29 | Treatment 4 | Chorum 7336 ELA Medical or InSync 8040 Medtronic | 6MWT | QOL (main secondary outcome); peak O_2_ uptake; hospital admissions because of decompensated heart failure; patient's preference with regard to pacing (active vs. inactive) at the end of crossover; death
| | 3 mo. | | | | | | | Control 3 | Transvenous
Cazeau 1996^99^ | France | Single-arm trial | None | 8 | 0 | - | 6 | - | 0 | Chorus TM 6234 Ela Medical, Medtronic Thera 7940 DR Transthoracic (7) | Potential hemodynamic benefit of CRT | Not stated
| | 2 mo.- 1 yr. | | | | | | | | Transvenous (1)
Filho 2002^98^ | Brazil | RCT cross-over | Rt. uni-ventricular pacing | 24 | 0 | - | - | - | 0 | Not reported | NYHA | QRS; mortality; LVEF; hospitalization
| | 30, 90, 180 days | | | | | | | | Transthoracic
Gras 2002^100^ INSYNC Italian Registry | Europe Canada | Single-arm trial | None | 117 | 0 | - | 103 | - | 9 | InSync Model 8040, Medtronic | Feasibility, safety and long term effects | NYHA, QRS duration, 6MWT, QOL
| | up to 1 yr. | | | | | | | | Transvenous
Guidant 2002^73^ CONTAK-CD FDA Report | US. (47 sites) | RCT | Pacer “Inactive” | 581 | 15 | 490 | 245 | 245 | Treatment 3 | CONTAK-CD | All-cause mortality; CHF hospitalizations; ventricular tachyarrhythmia requiring device intervention | Peak O_2_ consumption; QOL; 6MWT, all adverse events
| | Phase I period 1 of cross-over 3 mo | | | | | | | Control 1 | Transvenous and Transthoracic
| | Phase II parallel 6 mo
Krahn 2002^101^ | Canada | Single-arm trial | None | 45 | 0 | - | 40 | - | - | Medtronic InSync pacemaker or ICD or Guidant ContakTM or ICD | QOL; NYHA | Mortality, electrocardiographic measures; transplants
| | 1, 3, 6 mo. then q 6 mo. | | | | | | | | Transvenous
Kuhlkamp 2002^102^ | Germany | Single-arm trial | None | 84 | 0 | - | 81 | - | - | InSync Model 7272 Medtronic | Not stated | 6MWT; QOL; NYHA; complications; death
| | 3 mo. | | | | | | | | Transvenous
Leclercq 2000^96^ | France | Single-arm trial | None | 37 | 0 | 34 | 49 | - | - | Various models Medtronic | Mortality | NYHA;electrocardiographic measures; exercise tolerance.
| | 1, 3, 6 mo. then q 6 m | | | | | | | | Transvenous
| | | | | | | | | | Transthoracic
Leclercq 2002^75^ MUSTIC-AF | Europe (15 sites) | RCT cross-over 3 mo. | Rt. ventricular pacing | 64 | 10 | 43 | 25 | 18 | Treatment 1 | ELA medical, Medtronic | 6MWT | Peak O_2_ consumption; QOL; hospital admissions for decompensated heart failure; mortality; patient's preferred period at end of crossover
| | | | | | | | | Control 2 | Transvenous
| | | | | | | | | Both 2
Leclercq^104^ Unpublished | France | Single-arm trial | None | - | - | - | 125 | - | - | Not stated | Not stated | Survival, QRS duration and axis; NYHA; LVEF; exercise tolerance
| | 1, 3, 6 mo. Then q 6 mo. | | | | | | | | Transvenous
Leclercq 2003 RD-CHF** Unpublished | France | RCT cross-over | Rt. ventricular pacing | 56 | N/a | 44 | 22 | 22 | N/a | Transvenous | CHF hospitalization | N/a
| | 3 mo.
Medtronic 2001^36^ MIRACLE-ICD FDA Report, | US. & Canada (53 sites) | RCT parallel | Pacer “Inactive” | 660 | 36 | 555 | 272 | 282 | Treatment 7 | Model 7272 InSync ICD | NYHA; QOL; 6MWT | Adverse events; QRS; peak O_2_ uptake; echocardiographic indices; LV lead electrical performance; VT/VF therapy; CHF composite response; implant ventricular defibrillation criterion; ATP therapy; healthcare utilization; death
| | 6 mo. | | | | | | | Control 6 | Transvenous
Leon 2002^106^ | US. | Single-arm trial | None | 20 | 0 | - | 20 | - | 0 | Revised RV pacing system to CRT Medtronic leads | Improved ventricular function | Success of procedure; NYHA; QOL; hospitalization
| | | | | | | | | | Transvenous
Molhoek 2002^103^ | Netherlands | Single-arm trial | None | 40 | 0 | - | 40 | - | 0 | Easytrack 4512–80, Contak TR or CD Guidant, or InSync III | Clinical benefit, long-term prognosis | NYHA; QOL; 6MWT; electrocardiogram; hospitalization; mortality
| | 3, 6 mo. | | | | | | | | Transvenous

CRT-ICD = CRT with implanted cardioverter defibrillator; LVEDD = Left ventricular end diastolic diameter; LVEF = left ventricular ejection fraction; N/a = not available; NYHA = New York Heart Association; OPT = optimal pharmacological therapy; QOL = quality of life; RCT = randomized control trial; 6MWT = 6-minute walk test

* the intervention that cross-over studies received in the first period

** detailed data not available for Leclercq 2003 (RD-CHF) at the time this report was prepared

t excludes deaths and implant failures, where applicable

In total, 3938 patients were enrolled; of these, 3636 patients received CRT. Some patients were excluded or withdrew due to unsuccessful implants, death, heart transplantation, or miscellaneous reasons. The mean age was 65 ± 3 years, and 78% were male. Approximately 75% of each study population was NYHA class III (range 32% to100%), and 17% NYHA class IV (range 4 to 100%) (Table 10). Five studies^73,^ ^93,^ ^98,^ ^101,^ ^102^ included patients with NYHA class II symptoms (range 4% to 38%). Ethnic background was available from one trial in which 90% were Caucasian.^61^

Table 10. Baseline characteristics of patients in trials included in the efficacy review: CRT for CHF

| | | | | NYHA class | | | | ECG | | | Physical exam | | | Other co-morbidities
| | | | | II | III | IV | Atrial fibrillation | PR interval | QRS interval | LVEDD | Systolic BP | Diastolic BP | HR
Trial name | Study Group | Males n (%) | Age mean SD | Ischemic % | % | % | % | n (%) | mean SD (msec) | mean SD (msec) | mean SD (mm) | mean SD | mean SD | mean SD | LBBB % | LVEF %
Abraham 2002^61^ MIRACLE | CRT | 155 (68) | 64 +/- 11 | 50 | - | 90 | 10 | 0 | - | 167 +/- 21 | 70 +/- 10 | 114 +/- 18 | 69 +/- 10 | 73 +/- 13 | - | 22 +/- 6
| Control | 153 (68) | 65 +/- 11 | 58 | - | 91 | 9 | 0 | - | 165 +/- 20 | 69 +/- 10 | 115 +/- 18 | 68 +/- 10 | 75 +/- 13 | - | 22 +/- 6
Auricchio 2002^62^ PATH-CHF | CRT first | 11 (46) | 59 +/- 7 | 42 | - | 88 | 13 | 0 | 190 +/- 34 | 174 +/- 30 | 71 +/- 10 | - | - | 77 +/- 16 | 88 | 21 +/- 6
| Control first | 10 (59) | 60 +/- 5 | 6 | - | 82 | 18 | 0 | 207 +/- 30 | 178 +/- 34 | 75 +/- 13 | - | - | 80 +/- 13 | 100 | 20 +/- 7
| All | 21 (50) | 60 +/- 7 | 29 | - | 86 | 14 | 0 | 196 +/- 33 | 175 +/- 32 | 73 +/- 11 | - | - | 78 +/- 15 | 93 | 21 +/- 7
Bristow 2003^60^ COMPANION | CRT | 413 (67) | 65 | 54 | - | 87 | 13 | 0 | - | 159 | - | - | - | - | 69 | 22
| Control | 213 (69) | 67 | 59 | - | 82 | 18 | 0 | - | 156 | - | - | - | - | 70 | 23
| CRT-ICD | 399 (67) | 66 | 55 | - | 86 | 14 | 0 | - | 159 | - | - | - | - | 73 | 23
Cazeau 2001^74^ MUSTIC-SR | CRT first | 19 (66) | 64 +/- 11 | - | - | 100 | - | 0 | - | 172 +/- 22 | - | - | - | - | - | -
| Control first | 24 (83) | 64 +/- 8 | - | - | 100 | - | 0 | - | 175 +/- 19 | - | - | - | - | - | -
| All | 43 (74) | 64 +/- 9 | 37 | - | 100 | - | 0 | 215 +/- 43 | 174 +/- 20 | 73 +/- 10 | - | - | - | - | 23 +/- 7
Cazeau 1996^99^ | All | 7 (88) | 66 +/- 5 | 50 | - | | 100 | 3 (38) | 200 +/- 20 | 200 +/- 35 | - | - | - | - | 25 | 22 +/- 8
Filho 2002^98^ | All | 23 (96) | 55 +/- 13 | 38 | 33 | 67 | 4 | - | 225 +/- 80 | 181 +/- 31 | - | - | - | - | 100 | 19 +/- 5.2
Gras 2002^100^ INSYNC Italian Registry | All | 81 (77) | 67 +/- 10 | 48 | 0 | 68 | 32 | 0 | - | 178 +/- 28 | 72 +/- 10 | - | - | - | - | 22 +/- 6
Guidant 2002^73^ CONTAK-CD FDA report | CRT II–IV | 210 (85) | 66 +/- 11 | 67 | 32 | 60 | 8 | 0 | 205 +/- 42 | 160 +/- 27 | - | 118 +/- 21 | 67 +/- 12 | 73 +/- 12 | 54 | 21 +/- 7
| Control II–IV | 211 (83) | 66 +/- 11 | 70 | 33 | 57 | 10 | 0 | 202 +/- 49 | 156 +/- 26 | - | 118 +/- 21 | 69 +/- 12 | 75 +/- 14 | 55 | 22 +/- 7
| CRT III/IV | 90 (77) | 66 +/- 11 | 65 | 17* | 73 | 10 | 0 | 204 +/- 41 | 164 +/- 27 | - | 116 +/- 20 | 68 +/- 12 | 75 +/- 13 | 50 | 21 +/-6
| Control III/IV | 86 (78) | 66 +/- 11 | 71 | 10* | 71 | 19 | 0 | 200 +/- 54 | 152 +/- 24 | - | 117 +/- 23 | 67 +/- 14 | 74 +/-15 | 54 | 21 +/- 6
Krahn 2002^101^ | All | 37 (82) | 65 +/- 10 | 69 | 6 | 76 | 18 | 15 (33) | 240 +/- 63 | 166 +/- 20 | - | - | - | - | 98 | 19 +/- 5
Kuhlkamp 2002^102^ | All | 74 (91) | 64 +/- 9 | - | 32 | 59 | 9 | 19 (23) PAFr 10 (12 AF | - | 170 +/- 30 | 71 +/- 11 | - | - | - | - | 25 +/-7
Leclercq 2002^75^ MUSTIC-AF | CRT first | 21 (84) | 65 +/- 9 | - | - | 100 | - | 25 (100) | - | 209 +/- 21 | 70 +/- 9 | - | - | 75 +/- 6 | - | 23 +/- 7
| Control first | 14 (78) | 66 +/- 9 | - | - | 100 | - | 18 (100) | - | 208 +/- 12 | 66 +/- 7 | - | - | 74 +/- 5 | - | 30 +/- 12
| All | 35 (81) | 65 +/- 8 | 43 | - | 100 | - | 43 (100) | - | 209 +/- 18 | 68 +/- 8 | - | - | 74 +/- 5 | - | 26 +/- 10
Leclercq 2000^107^ | All | 34(92) | 68 +/- 8 | 38 | 0 | 70 | 30 | 14 (28) | 260 +/- 30 | 181 +/- 23 | 87 +/- 8 | - | - | - | - | 23 +/-5
Leclercq^104^ unpublished | All | 110 (88) | 68 +/- 9 | 38 | - | 68 | 32 | 36 (29) | 248 +/- 56 | 183 +/- 29 | 74 +/- 8.5 | - | - | - | - | 21 +/- 6
Leclercq 2003 RD-CHF** Unpublished | - | N/a | 73 +/- 8 | N/a | 0 | N/a | N/a | 23 | N/a | N/a | N/a | N/a | N/a | N/a | N/a | 25 +/- 9
Leon 2002^106^ | All | 17 (85) | 70 +/- 11 | 55 | 0 | 60 | 40 | 20 (100) | - | 213 +/- 40 | 68 +/- 8 | - | - | - | - | 22 +/- 7
Medtronic 2001^36^ MIRACLE-ICD FDA report 2001 | CRT II–IV | 217 (80) | 66 +/- 12 | 38 | 32 | 60 | 8 | 16 (6) | - | 166 +/- 23 | 71 +/- 9 | 113 +/- 19 | 67 +/- 11 | 73 +/- 13 | 10 | 21 +/- 7
| Control II–IV | 231 (82) | 66 +/- 11 | 32 | 38 | 55 | 7 | 12 (4) | - | 163 +/- 22 | 70 +/- 9 | 113 +/- 17 | 68 +/- 12 | 73 +/- 13 | 0 | 21 +/- 7
| CRT III/IV | 142 (76) | 67 +/- 11 | 64 | - | 88 | 12 | 49 (26) | - | 165 +/- 22 | 70 +/- 9 | - | - | 71 +/- 12 | 75 | 21 +/- 7
| Control III/IV | 136 (77) | 68 +/- 9 | 75 | - | 89 | 11 | 31 (18) | - | 162 +/ -22 | 71 +/- 9 | - | - | 72 +/- 13 | 71 | 20 +/- 6
Molhoek 2002^103^ | All | 31 (78) | 64 +/- 10 | 48 | mean = 3.3 +/- 0.5 | | | 4 (10) | - | range 120–240 | - | - | - | - | 100 | 24+/- 9

CRT = cardiac resynchronization therapy; FDA = Food and Drug administration; LBBB = left bundle branch block; LVEF = left ventricular ejection fraction; LVEDD = left ventricular end diastolic diameter; N/a = not available; NYHA = New York Heart association; SD = standard deviation

* pre-implant assessment

** detailed data not available for Leclercq 2003 (RD-CHF) at the time this report was prepared

Kuhlkamp^102^ required participants be survivors of a cardiac arrest and have sustained ventricular tachycardia; otherwise no studies specifically based inclusion on the etiology of their heart failure. Patients with correctable valvular disorders, hypertrophic or restrictive cardiomyopathy, unstable angina, or acute myocarditis were excluded. Four studies did not state exclusion criteria.^99,^ ^102,^ ^103,^ ^106^ Ischemic etiology ranged from 29%^62^ to 69%.^101^ Other comorbidities such as diabetes mellitus or renal failure were reported in only one study.^36^

Eleven studies limited inclusion to patients with an ejection fraction <35%, one restricted it to <30%,^98^ one to <25%,^60^ and 3 did not specify this criterion.^62,^ ^99,^ ^101^ The mean ejection fraction ranged from 19% to 26%. Nine studies specified a left ventricular end diastolic dimension inclusion criterion of ≥55 mm^60,^ ^61,^ ^74,^ ^75,^ ^93,^ ^96,^ ^100,^ ^102,^ ^104^ or ≥ 60 mm. The reported mean left ventricular end diastolic dimension for the trials ranged from 68 mm to 74 mm.

QRS width was a criterion for 13 studies, with six specifying ≥ 120 msec,^60,^ ^62,^ ^73,^ ^103,^ ^107^ four studies ≥ 130 msec,^61,^ ^93,^ ^101,^ ^102^ two trials >150 msec,^74,^ ^100^ and one > 200 msec.^75^ Ten of the 16 studies reported a mean QRS between 158 msec and 180 msec, and six ranged from 180 msec to 213 msec.^70,^ ^75,^ ^96,^ ^99,^ ^104,^ ^106^ In the nine studies that reported the presence of left bundle branch block, the mean was 68% (range 0 to 100%).

Five studies were restricted to patients in normal sinus rhythm,^60,^ ^62,^ ^74,^ ^100^ but two were restricted to patients with atrial fibrillation.^96,^ ^106^ In the others, 6% to 38% of patients had atrial fibrillation. Eight studies reported PR intervals that ranged from 198 msec to 248 msec, and two required a prolonged PR interval >150 msec for inclusion.^60,^ ^62^ Three studies required a six-minute walk test result of ≤ 450 meters as an inclusion criterion.^61,^ ^74,^ ^75^ The physical exam findings of systolic blood pressure (range 113 mmHg to 118 mmHg), diastolic blood pressure (range 67 mmHg to 68 mmHg), and heart rate (range 73 to 78 bpm) at baseline were all similar to other studies in heart failure.^97^ (The inclusion and exclusion criteria for the individual studies are detailed in Appendix C: Table C-2).

Concomitant medication use was specified in all but the PATH CHF^62^ and Molhoek^103^ studies (Table 11). ACE inhibitors were required in all studies, beta-blockers were required in three,^60,^ ^61,^ ^101^ and spironolactone was only required in COMPANION.^60^ Importantly, four studies reported 31% to 50% use of amiodarone,^62,^ ^74,^ ^98,^ ^100^ and 38% of patients in the MIRACLE ICD trial^36^ were on non-beta-blocker anti-arrhythmic agents. Eleven studies reported that 32% to 100% of participants were on digoxin and 90% to 100% were taking diuretics. Table 11 (see end of chapter) details baseline medication use by study.

Table 11. Baseline drug therapy in included patients in the safety review: CRT for CHF

| | Medications
Trial name | Study Groups | ACE % | ARB % | BB % | Spironolactone % | Digoxin % | Nitrates % | Others Name %
Abraham 2002^61^ MIRACLE | CRT | 93* | - | 62 | - | 78 | - | Diuretics (94)
| Control | 90* | - | 55 | - | 79 | - | Diuretics (93)
Auricchio 2002^62^ PATH-CHF | CRT | 96** | - | 71 | - | ** | 71 | Amiodarone (29)
| Control | 100** | - | 65 | - | ** | 71 | Amiodarone (35)
| All | 95** | - | 67 | - | ** | 69 | Amiodarone (30)
Bristow 2003^60^ COMPANION | CRT | 89* | * | 68 | 53 | - | - | Diuretics (100); digoxin (100)
| Control | 89* | * | 66 | 55 | - | -
| CRT-D | 90* | * | 68 | 55 | - | -
Cazeau 2001^74^ MUSTIC-SR | All | 96* | * | 28 | 22 | 48 | - | Amiodarone (31), diuretics (100)
Cazeau 1996^99^ | All | 100 | - | - | - | - | - | All on maximal medical therapy; 4 on IV dobutamine &/or dopamine
Filho 2002^98^ | All | 92 | - | - | 42 | 100 | 13** | Diuretics (100); carvedilol (29); amiodarone (50);
Gras 2002^100^ INSYNC Italian Registry | All | 70 | 16 | 17 | - | 58 | - | Amiodarone (50); diuretic (93); vasodilators (17); CCB (15) anticoagulants (34); IV inotropic support (2)
Guidant 2002^73^ CONTAK-CD FDA report | CRT, II–IV | 86* | * | 48 | - | 69 | - | Diuretics (88)
| Control, II–IV | 89* | * | 46 | - | 68 | - | Diuretics (83)
| CRT, III/IV | 81* | * | 45 | - | 72 | - | Diuretics (92)
| Control, III/IV | 89* | * | 40 | - | 68 | - | Diuretics (86)
Krahn 2002^101^ | All | 84 | - | 56 | - | - | - | Antiarrhythmic agents (47); diuretic (100)
Kuhlkamp 2002^102^ | All | 85 | - | 54 | - | 32 | 31 | Diuretics (54); anticoagulants (56); antiarrhythmics (58)
Leclercq 2002^75^ MUSTIC-AF | All | 100* | * | 23 | 16 | 58 | - | -
Leclercq 2000^96^ | All | 100 | - | - | - | 60 | - | Diuretics (100), captopril (95 +/- 30mg/d)
Leclercq^104^ unpublished | All | 98 | - | 34 | - | 60 | - | Diuretics (100),
Leclercq 2003 RD-CHF^***^ Unpublished | N/a | N/a | N/a | N/a | N/a | N/a | N/a | N/a
Leon 2002^106^ | All | 90 | - | 25 | - | 60 | - | Diuretics (95)
Medtronic 2001^36^ MIRACLE-ICD FDA report | CRT, II–IV | 93 | - | 63 | - | 71 | 31 | Diuretics (91); anti-depressant (16); CCB (6); antiarrhythmic (40); positive ionotrope (71); anti-coagulant (77).
| Control, II–IV | 90 | - | 59 | - | 72 | 30 | Diuretics (90); anti-depressant (17); CCB (6); anti-coagulant (79); antiarrhythmic (33); positive ionotrope (72)
| CRT, III/IV | 92 | - | 63 | - | 76 | 36 | Diuretics (93); anti-depressant (19); CCB (7); anti-coagulant (77); antiarrhythmic (42); positive ionotrope (76)
| Control, III/IV | 88 | 32 | 58 | - | 73 | 33 | Diuretics (94); anti-depressant (20); CCB (6); anti-coagulant (81); antiarrhythmic (32); positive ionotrope (73)
Molhoek 2002^103^ | All | Not stated | - | - | - | - | - | -

ACE= angiotensin-converting-enzyme inhibitors; ARB= angiotension-receptor blocker; BB= beta blocker; CCB= calcium channel blocker

* ACE or ARB

** receiving nitrates or hydralazine

*** detailed data not available for Leclercq 2003 (RD-CHF) at the time this report was prepared

### Quality of Included Studies

Overall, the studies were rated as having ‘good’ quality on the Downs and Black^59^ scoring system. Eight studies were described as randomized (three parallel trials,^36,^ ^95,^ ^108^ five crossover trials,^62,^ ^73,^ ^74,^ ^96,^ ^98^ and the remaining eight were prospective cohort studies.^99,^ ^96,^ ^100–104,^ ^106^ Reporting was generally good with 8 of 16 rating 11/11, the rest ranging from 7 to 10. External validity assessment posed some problems because authors did not report the source population for patients or the proportion of eligible patients selected for inclusion, nor compare the distribution of main confounding factors with the source population. (For this review we defined the source population as those with symptomatic CHF.) Since this procedure can only be performed in specialist centers, we determined that all facilities were representative. Internal validity concerning assessment of bias ranged from 5/7 to 7/7; the lack of blinding was the main shortfall. Four studies were double-blind,^36,^ ^61,^ ^62,^ ^73^ two were single-blind (i.e., the patient),^74,^ ^75^ and the remaining trials were open-label. Internal validity assessments concerning confounding ranged between 1/6 to 6/6, with only two studies receiving 2 or less.^96,^ ^100^ Many authors did not state the period of time over which patients were recruited, the source of patients, or how the randomization code was generated and concealed. Withdrawals and dropouts were clearly described in all studies except COMPANION.^60^ Four studies included a power calculation,^60,^ ^61,^ ^74,^ ^75^ and nine had sufficient sample sizes to determine a clinically important effect.^36,^ ^60–62,^ ^73–75,^ ^98,^ ^104^

The majority of studies that reported sponsorship received funding from industry. Three were sponsored by Guidant Corporation,^60,^ ^62,^ ^73^ six by Medtronic,^36,^ ^61,^ ^74,^ ^75,^ ^102,^ ^106^ and three received technical support from ELA Recherche.^74,^ ^75,^ ^99^ The two MUSTIC trials^74,^ ^75^ and Krahn^101^ received funds from independent sources. Four studies did not report a funding source.^96,^ ^98,^ ^100,^ ^104^ Methodological quality of the trials in the safety review are summarized in Table 12 (end of chapter).

Table 12. Methodological quality assessments of included studies: safety review

Study name | Sponsor | Downs and Black Quality Score^59^
| | Reporting Maximum 11 | External validity Maximum 3 | Internal validity [bias] maximum 7 | Internal validity [confounding] Maximum 6 | Power Maximum 2 | Overall Maximum 29
Abraham 2002 MIRACLE^61^ | Medtronic Inc. | 11 | 2 | 7 | 6 | 2 | 28
Auricchio 2002^62^ PATH-CHF | Guidant Corporation | 11 | 2 | 7 | 5 | 1 | 26
Bristow 2003^60^ COMPANION | Guidant Corporation | 8 | 1 | 5 | 4 | 2 | 20
Cazeau 2001^74^ MUSTIC-SR | ELA Recherche, Medtronic, Swedish Heart and Lung Association; Swedish Medical Research Council | 11 | 1 | 6 | 5 | 2 | 25
Cazeau 1996^99^ | technical support from ELA Recherche | 9 | 1 | 5 | 4 | 0 | 19
Filho 2002^98^ | None indicated | 7 | 1 | 5 | 4 | 1 | 18
Gras 2002^100^ INSYNC Italian Registry | None indicated | 9 | 1 | 5 | 1 | 1 | 17
Guidant 200^173^ CONTAK-CD FDA report | Guidant Corporation | 11 | 2 | 7 | 4 | 1 | 25
Krahn 2002^101^ | Heart and Stroke Foundation of Ontario | 10 | 3 | 5 | 4 | 0 | 22
Kuhlkamp 2002^102^ | Medtronic Inc. | 11 | 1 | 5 | 3 | 0 | 20
Leclercq 2002^75^ MUSTIC-AF | ELA Recherche, Medtronic, European Society of Cardiology, Centre Hospitalier Universitaire de Rennes; Swedish Heart and Lung Association, Swedish Medical Research Council | 11 | 2 | 6 | 5 | 2 | 26
Leclercq 2000^96^ | None indicated | 10 | 2 | 5 | 2 | 0 | 19
Leclercq Unpublished^104^ | None indicated | 10 | 2 | 5 | 3 | 1 | 21
Leclercq 2003 RD-CHF* Unpublished | N/a | N/a | N/a | N/a | N/a | N/a | N/a
Leon 2002^106^ | Medtronic provided fellowship support | 11 | 3 | 5 | 3 | 0 | 22
Medtronic 2001^36^ MIRACLE-ICD FDA report | Medtronic Inc | 11 | 1 | 7 | 3 | 1 | 23
Molhoek 2002^103^ | Medtronic Inc. | 10 | 2 | 5 | 3 | 0 | 20

N/a = not available

* detailed data not available for Leclercq 2003 (RD-CHF) at the time report prepared

## Quantitative Results

### Efficacy Review

The nine trials included 2755 patients with NYHA Class III or IV CHF, and 461 patients with NYHA Class II symptoms.

All-cause mortality. Based on data pooled from all nine randomized controlled trials (311 deaths in patients with NYHA class III or IV symptoms at baseline, 14 deaths in those with NYHA class II symptoms), CRT significantly reduced all-cause mortality, with a relative risk of 0.75 (95% CI 0.60 to 0.93) (Figure 4 end of chapter). There was no significant statistical heterogeneity between trials (p=0.88, I-squared=0%). The results were identical when the analysis was restricted to patients with NYHA Class III or IV symptoms (RR 0.76, 95% CI 0.60 to 0.95). The all-cause mortality rate in the control patients with symptomatic heart failure (NYHA II–IV) was 14.9%, and the number needed to treat (NNT) to prevent one death was 27 in patients with symptomatic heart failure.

Figure 4. Meta-graph of all-cause mortality

Time-to-death analysis. The time-to-death analysis (4 trials; n=2769 patients) demonstrated that length of followup affects results with the survival curves separating after 3 months (Figure 5). Trials with longer followup periods reported greater survival benefits. When data were used for trials with a followup of six months or more,^36,^ ^60,^ ^61^ all-cause mortality remained significant with a relative risk of 0.70 (95% CI 0.56 to 0.89). The 12-month survival rate for the CRT group was 89% (95% CI 87% to 90%) and 83% (79% to 86%) for the non-CRT group; this difference was significant based on the log-rank test (p=0.005). To account for the separation of the curves at 3 months and since data were integrated from four studies, we used a Cox proportional hazards model (using study as a covariate) and only incorporated data from beyond the first three months. The hazard ratio was 0.59 (95% CI 0.43 to 0.81) for mortality after the first 3 months post-implantation.

Figure 5. Time to all-cause death

Note: The COMPANION Trial consisted of three arms. To avoid “double counting” in calculating summary estimates of treatment effect, we divided the 58 deaths in 308 control patients into 29 deaths in 154 controls in each comparison.

Cardiac mortality. Seven trials reported progressive heart failure mortality in NYHA Class II to IV patients (n=60 deaths/1647 patients); the relative risk strongly favored CRT, although it just failed to reach statistical significance using the (methodologically correct, but statistically conservative) random effects model (RR 0.60, 95% CI 0.36 to 1.01; Figure 6). Restricting this analysis to patients with NYHA Class III or IV symptoms gave similar results (RR 0.58, 95% CI 0.32 to 1.06).

Figure 6. Meta-graph of death due to congestive heart failure

Sudden cardiac death. Using data pooled from the eight trials that reported the cause of death, sudden cardiac death (n=28 deaths/1691 patients) was higher (although non-significantly) with CRT compared to controls (RR 1.99, 95% CI 0.95 to 4.16; Figure 7). This result was not statistically heterogeneous (p=0.98, I-squared=0%) and was similar if only trials of six months or longer were included or if only patients with NYHA Class III or IV were included (RR 1.89, 95% CI 0.76 to 4.70). Only one trial that included an implantable cardioverter defibrillator for all patients reported the cause of death; the risk for sudden cardiac death was non-significant (RR 1.89, 95% CI 0.35 to 10.21).^36^

Figure 7. Meta-graph of sudden cardiac death

Non-cardiac death. Pooled data from six trials (n= 17/1194 patients) did not demonstrate any significant differences in non-cardiac deaths between patients with CRT (RR 0.90, 95% CI 0.35 to 2.35; Figure 8). This result was not statistically heterogeneous (p=0.46, I-squared=0%). Restricting the analysis to patients in NYHA Class III or IV CHF did not alter this conclusion (RR 1.89, 95% CI 0.35 to 10.21).

Figure 8. Meta-graph of non-cardiac death

#### Morbidity and functional outcomes

Heart failure hospitalizations. Pooled results from the six trials that reported heart failure hospitalizations showed a relative risk of 0.68 (95% CI 0.41 to 1.12; Figure 9 end of chapter) in favor of CRT compared to control. This result was heterogeneous (p=0.01, I-squared=65%) and was also insignificant in the fixed effects analysis (RR 0.80, 95% CI 0.64 to 1.003). Restricting the analysis to patients with more advanced heart failure (those with NYHA Class III or IV symptoms) revealed significant reductions (RR 0.65, 95% CI 0.48 to 0.88; NNT=12) and was statistically homogeneous (p=0.31, I-squared=16%).

Figure 9. Meta-graph of hospitalizations due to congestive heart failure

Six-minute walk test. CRT was associated with an improved six-minute walk test distance, with a weighted-mean-difference of 23 meters in favor of CRT (95% CI 9 m to 38 m, Figure 10 end of chapter). This improvement was similar in those patients with NYHA Class III or IV symptoms (WMD 26 m, 95% CI 11 m to 41 m). However, this result was heterogeneous (p=0.06, I-squared=50%) in part due to one trial^74^ in which the control group worsened by 24 meters; the control groups in all other trials that reported baseline results showed an improvement. Although the data from the RD-CHF Trial were not available for pooling, the RD-CHF investigators reported statistically significant improvements in six-minute walk test distances with CRT (personal communication, Dr. Christophe Leclercq, November 2003).

Figure 10. Meta-graph of six-minute walk test

New York Heart Association Functional Class. We were able to meta-analyze data for NYHA Class from three studies (although five studies reported baseline and endpoint NYHA Class). Combining these three studies showed improvements in NYHA Class in 57% of CRT patients and 34% of controls (CRT was associated with a 1.63 times increased chance of improving at least one NYHA Class (95% CI 1.05 to 2.52), Figure 11). This result was statistically heterogeneous (p=0.04, I-squared=70%). In patients with NYHA Class III or IV symptoms, the relative risk improved slightly to 1.68 (95% CI 1.25 to 2.27). The data from MIRACLE ICD^61^ was not reported in a format that permitted pooling with the other 3 trials; however, the baseline median NYHA Class for both groups was III and the endpoint median was II in the CRT group and III in the control group. This improvement in NYHA Class was significant (p=0.01) and favored CRT; the specific statistical test used was not reported. In contrast, PATH CHF^62^ (which could also not be combined with the other trials due to the manner in which the data were reported) did not find a significant difference (p=0.36; Wilcox on matched-pairs test), although both groups showed significant improvement from baseline. Moreover, while the data from the RD-CHF Trial could not be pooled with the other trials, the RD-CHF investigators also reported statistically significant improvements in NYHA Class with CRT (personal communication, Dr. Christophe Leclercq, November 2003).

Figure 11. Meta-graph of changes in NYHA status

Quality of life. Quality of life was measured by the Minnesota Living With Heart Failure Instrument^109–111^ for six of the eight trials; pooled results showed a significant improvement in favor of CRT (weighted mean difference -5.5 points (95% CI -9 to -2 points; Figure 12). This result was highly statistically heterogeneous (p=0.008, I-squared=68%); however results were consistent in direction. Restricting the analysis to only those patients with NYHA Class III or IV symptoms increased the difference between the CRT and control groups (WMD -6.4 points, 95% CI -9.4 to -3.4 points), but the results remained significantly heterogeneous (p=0.07, I-squared=50%). These differences are clinically significant since the minimal clinically important difference for the Minnesota Living with Heart Failure Questionnaire has been established to be 5 points.^109–111^ Further, although the use of a different scale prevented pooling with the other trials, the RD-CHF Investigators reported statistically significant improvements in quality of life with CRT (personal communication, Dr. Christophe Leclercq, November 2003).

Figure 12. Meta-graph of quality of life (based on Minnesota Living with Heart Failure instrument)

Other outcomes. Peak oxygen consumption significantly improved in the CRT patients compared to the control patients (1.05 ml/kg/min versus 0.39 ml/kg/min; WMD 0.65 ml/kg/min, 95% CI 0.27 to 1.04 ml/kg/min). Ejection fraction also significantly improved in the CRT arm compared to the control arm (4.17% versus 0.82%; WMD 3.35%, 95% CI 1.22 to 5.48%). The QRS interval also showed greater improvement in the CRT group (-30 msec versus -2 msec for controls; WMD -28, 95% CI -47 msec to -9 msec). Other echocardiographic indices including mitral regurgitation jet area were not significantly different between groups; there were insufficient data that could be pooled for left ventricular end-diastolic or end-systolic diameters.

Sensitivity analyses. Many a priori subgroup and sensitivity analyses (including examining any interactions between the effects of CRT in patients with different etiologies of heart failure, or by ethnic background, gender, age, comorbidities, and baseline medication use) could not be performed due to the paucity of subgroup data in the trial reports and our inability to obtain individual patient-level data from each of the trial lists despite our requests.

Post-hoc, we explored the impact of ICDs on the efficacy of CRT using meta-regression (a between-study non-randomized comparison). When the data were pooled for all-cause mortality from the two trials that included an ICD in both the experimental and control arms (i.e., CRT+ICD versus medical therapy +ICD),^36,^ ^73^ the relative risk was 0.84 (95% CI 0.54 to 1.28). On the other hand, pooled data from the other five trials comparing CRT versus medical therapy demonstrated a relative risk of 0.78 (95% CI 0.56 to 1.08) with CRT (Figure 13).^61,^ ^62,^ ^74,^ ^75^ This difference was not statistically significant (p=0.80), supporting the assertion that the benefits of CRT on all-cause mortality are not appreciably altered by addition of an ICD. Using the same meta-regression model, secondary outcomes (including heart failure hospitalizations, six-minute walk test, quality of life, and NYHA improvements) were not significantly different in patients with, or without an ICD, in addition to their biventricular pacemaker. Of note, while the data from COMPANION^60^ could not be used in the meta-regression for ICDs (since none of the arms in COMPANION^60^ consisted of ICD alone), the COMPANION^60^ data does provide the only direct comparison between CRT plus ICD versus CRT alone. This analysis did approach statistical significance (p=0.07) in favor of the CRT plus ICD group for all-cause mortality; however, the reductions in heart failure hospitalizations were similar in CRT-treated patients with/without ICDs. Until the detailed data from the COMPANION^60^ sub-analyses are made available, the most conservative conclusion that can be made at this stage is that the benefits of CRT are similar with or without ICDs.

Figure 13. Meta-graph of all-cause mortality by cardioverter defibrillator vs non-cardioverter defibrillator

Post-hoc we also explored the relationship between the baseline use of beta-blockers and/or digoxin with the impact of CRT on all-cause mortality. Both meta-regressions were non-significant (p=0.37 and p=0.31, respectively), suggesting that the benefits of CRT are not modified by use of these medications. However, and as expected, the linear trends showed improved survival with greater use of beta-blockers.

Publication bias could not be quantitatively measured since all of the smaller studies had shorter followup times, hence confounding results. In a post-hoc subgroup analysis examining published versus unpublished studies, there was no appreciable difference between effect estimates for all-cause mortality (p=0.64).

Fixed effects estimates did not substantially alter the results of our meta-analysis (although the confidence intervals were naturally narrower and, as a result, the analysis for progressive heart failure mortality (RR 0.59, 95% CI 0.35 to 0.98) reached statistical significance).

### Safety Review

As previously described, seventeen studies were used to examine the safety of CRT. Tables 13 and 14 report peri-implantation and post-implantation risks from individual studies as well as pooled results. In pooling data, we did not include studies that did not report any data for particular outcomes. However, where appropriate, we performed sensitivity analyses by assuming zero occurrences of that endpoint in that study.

Table 13. Peri-implant risks for cardiac resynchronization therapy

Study | n/N | Simple Pool
| | Risk % [95% CI]
Peri-implant deaths
MUSTIC-SR 2001^74^ | 0/64 | 0
MUSTIC-AF 2002^75^ | 0/59 | 0
PATH-CHF 2002^62^ | 0/41 | 0
MIRACLE 2002^61^ | 2/571 | 0.4 [0.1,1.4]
MIRACLE-ICD 2003^94^ | 0/429 | 0
COMPANION unpub^60^ | 5/617 | 0.8 [0.3,2.0]
COMPANION-ICD unpub^60^ | 3/595 | 0.5 [0.1,1.6]
Cazeau 1996^99^ | 1/7 | 14.3 [8.4,54.0]
Filho 2002^98^ | 0/24 | 0
Leclercq unpub^104^ | 0/139 | 0
Total [N=10] | 13/3113 | 0.4 [0.2,0.7]
Sensitivity Total [N=16] | 13/3456 | 0.4 [0.2,0.7]
Implant successes
MUSTIC-SR 2001^74^ | 59/64 | 92.2 [82.0,97.1]
MUSTIC-AF 2002^75^ | 54/59 | 91.5 [80.6,96.8]
MIRACLE 2002^61^ | 528/571 | 92.5 [89.9,96.8]
PATH-CHF 2002^62^ | 41/41 | 100
MIRACLE-ICD 2003^94^ | 379/429 | 88.3 [84.8,91.1]
COMPANION unpub^60^ | 538/617 | 87.2 [84.2,89.7]
COMPANION-ICD unpub^60^ | 540/595 | 90.8 [88.1,92.9]
CONTAK-CD unpub^73^ | 501/567 | 88.4 [85.4,90.8]
RD-CHF unpub^#^ | 45/56 | 80.4 [67.2,89.3]
Cazeau 1996^99^ | 6/7 | 85.7 [42.0,99.2]
Gras 2002^100^ | 125/139 | 89.9 [83.4,94.2]
Krahn 2002^101^ | 40/45 | 88.9 [75.2,95.8]
Kuhlkamp 2002^102^ | 81/84 | 96.4 [89.2,99.1]
Leon 2002^106^ | 20/20 | 100
Filho 2002^98^ | 24/24 | 100
Molhoek 2002^103^ | 40/40 | 100
Leclercq unpub^104^ | 125/139 | 89.9 [83.4,94.2]
Total [N=16]* | 3124/3475 | 89.9 [88.8,90.9]
Related to left ventricular lead
MUSTIC-SR 2001^74^ | 5/64 | 7.8 [2.9,18.0]
MUSTIC-AF 2002^75^ | 5/59 | 8.5 [3.2,19.4]
MIRACLE-ICD 2003^36^ | 31/429 | 7.2 [5.0,10.2]
CONTAK-CD unpub^73^ | 17/517 | 3.3 [2.0,5.3]
Gras 2002^100^ | 12/117 | 10.3 [5.6,17.6]
Krahn 2002^101^ | 6/45 | 13.3 [5.5,27.5]
Kuhlkamp 2002^102^ | 4/84 | 4.8 [1.5,12.4]
Filho 2002^98^ | 0/24 | 0
Total [N=8] | 80/1339 | 6.0 [4.7,7.2]
Sensitivity Total [N=14]** | 80/2055 | 3.9 [3.1,4.8]
Related to the device and battery
PATH-CHF 2002^62^ | 3/41 | 7.3 [1.9,21.0]
MIRACLE 2002^61^ | 2/571 | 0.4 [0.06,1.4]
MIRACLE-ICD 2003^94^ | 3/429 | 0.7 [0.2,2.2]
CONTAK-CD unpub^73^ | 7/517 | 1.4 [0.6,2.9]
Filho 2002^98^ | 0/24 | 0
Total [N=5] | 15/1582 | 0.9 [0.6,1.6]
Sensitivity Total [N=14]** | 15/2055 | 0.7 [0.4,1.2]
Related to implant procedure and/or tools
MIRACLE 2002^61^ | 35/571 | 6.1 [4.4,8.5]
MIRACLE-ICD 2003^94^ | 19/429 | 4.4 [2.8,7.0]
CONTAK-CD unpub^73^ | 50/517 | 9.7 [7.3,12.6]
Gras 2002^100^ | 3/117 | 2.6 [0.7,7.9]
Krahn 2002^101^ | 4/45 | 8.9 [2.9,22.1]
Kuhlkamp 2002^102^ | 4/84 | 4.8 [1.5,12.4]
Leon 2002^106^ | 0/20 | 0
Filho 2002^98^ | 0/24 | 0
Total [N=8] | 115/1807 | 6.4 [5.3,7.6]
Sensitivity Total [N=14]** | 115/2055 | 5.6 [4.7,6.7]
Related to heart function
MIRACLE 2002^61^ | 1/571 | 0.2 [0.009,1.1]
MIRACLE-ICD 2003^94^ | 11/429 | 2.6 [1.4,4.7]
Cazeau 1996^99^ | 1/7 | 14.3 [8.4,54.0]
Filho 2002^98^ | 0/24 | 0
Total [N=4] | 13/1031 | 1.3 [0.7,2.2]
Sensitivity Total [N=14]** | 13/2055 | 0.6 [0.4,1.1]

* only safety outcome that includes data from RD-CHF

** COMPANION omitted - full report not available; Leclercq 2002 omitted, - there was 10% or 14/139 failed implants but they did not specify the event

Table 14. Post-implantation risks of cardiac resynchronization therapy

Study | n/N | Simple Pool
| | Risk % [95% CI]
Mechanical malfunction
MUSTIC-SR 2001^74^ | 2/58 | 3.4 [0.6,13.0]
MUSTIC-AF 2002^75^ | 2/54 | 3.7 [0.6,13.8]
CONTAK-CD unpub^73^ | 22/448 | 4.9 [3.2,7.5]
MIRACLE-ICD unpub^36^ | 25/364 | 6.9 [4.6,10.1]
Leclercq 2000^96^ | 3/37 | 8.1 [2.1,23.0]
Gras 2002^100^ | 4/103 | 3.9 [1.3, 10.2]
Kuhlkamp 2002^102^ | 1/84 | 1.2 [0.1,7.4]
Filho 2002^98^ | 3/24 | 12.5 [3.3,33.5]
Leclercq unpub^104^ | 25/125 | 20.0 [13.6,28.3]
Total [N=9] | 87/1297 | 6.7 [5.4,8.2]
Sensitivity Total [N=15]* | 87/1968 | 4.4 [3.6,5.4]
Lead dislodgement
MUSTIC-SR 2001^74^ | 8/58 | 13.8 [6.6,25.9]
MUSTIC-AF 2002^75^ | 5/54 | 9.3 [3.5,21.1]
MIRACLE 2002^61^ | 30/524 | 5.7 [4.0,8.2]
CONTAK-CD unpub^73^ | 31/448 | 6.9 [4.8,9.8]
MIRACLE-ICD unpub^36^ | 46/364 | 12.6 [9.5,16.6]
Cazeau 1996^99^ | 2/6 | 33.3 [6.0,75.9]
Leclercq 2000^96^ | 2/37 | 5.4 [0.9,19.5]
Gras 2002^100^ | 10/103 | 9.7 [5.0,17.5]
Krahn 2002^101^ | 4/40 | 10.0 [3.3,24.6]
Kuhlkamp 2002^102^ | 7/84 | 8.3 [3.7,17.0]
Filho 2002^98^ | 0/24 | 0
Molhoek 2002^103^ | 3/40 | 7.5 [2.0,21.5]
Leclercq unpub^104^ | 15/125 | 12.0 [7.1,19.3]
Total [N=13] | 163/1907 | 8.5 [7.4,9.9]
Sensitivity Total [N=15]* | 163/1968 | 8.3 [7.1,9.6]
Infection
MIRACLE 2002^61^ | 7/524 | 1.3 [0.6,2.9]
MIRACLE-ICD unpub^36^ | 2/364 | 0.5 [0.1,2.2]
Gras 2002^100^ | 2/103 | 1.9 [0.3,7.5]
Kuhlkamp 2002^102^ | 2/84 | 2.4 [0.4,9.1]
Filho 2002^98^ | 1/24 | 4.2 [0.2,23.1]
Leclercq unpub^104^ | 3/125 | 2.4 [0.6,7.4]
Total [N=6] | 17/1224 | 1.4 [0.8,2.3]
Sensitivity Total [N=15]* | 17/1968 | 0.9 [0.5,1.4]
Arrhythmias associated with CRT
MUSTIC-AF 2002^75^ | 1/54 | 1.9 [0.1,11.2]
PATH-CHF 2002^62^ | 4/41 | 9.8 [3.2,24.1]
MIRACLE-ICD unpub^36^ | 3/364 | 0.8 [0.2,2.6]
Filho 2002^98^ | 0/24 | 0
Molhoek 2002^103^ | 1/40 | 2.5 [0.1,14.7]
Total [N=5] | 9/523 | 1.7 [0.8,3.4]
Sensitivity Total [N=15]* | 9/1968 | 0.5 [0.2,0.9]
Pain
Krahn 2002^101^ | 1/40 | 2.5 [0.1,14.7]
Filho 2002^98^ | 3/24 | 12.5 [3.3,33.5]
Total [N=2] | 4/64 | 6.3 [2.0,16.0]
Sensitivity Total [N=15]* | 4/1968 | 0.2 [0.07,0.6]

* COMPANION omitted - full report not available

Peri-implantation risks. Ten studies reported data on deaths while undergoing implantation of a biventricular pacemaker (Table 13, end of chapter). There were 13 deaths in 3113 patients (pooled risk 0.4%, 95% CI 0.2% to 0.7%); a sensitivity analysis assuming any studies that did not report mortality had zero occurrences yielded the same estimate. Immediate deterioration in heart function was noted after 1.3% (95% CI 0.7% to 2.2%) of implantation procedures. Implants of devices were successful in 89.9% (95% CI 88.8% to 90.9%) of attempts in 3475 patients from 17 studies; this rate did not vary, but trended toward improvement, by year of publication.

Problems with implantation of the left-ventricular lead were encountered in 6.0% (95% CI 4.7% to 7.2%) of cases. Assuming that any studies failing to report any implantation problems had zero occurrences in sensitivity analysis led to a reduced estimate of 3.9% (95% CI 3.1% to 4.8%). The device or battery was problematic in 0.9% (95% CI 0.6% to 1.6%) of cases (0.7%, 95% CI 0.4% to 1.2% with sensitivity analysis), and the procedure or equipment used for the procedure was reported to be a problem in 6.4% (95% CI 5.3% to 7.6%) of cases attempted (reduced to 5.6%, 95% CI 4.7% to 6.7% in sensitivity analysis). Further detailed information on the type of equipment failure was not uniformly available, so pooling of results was not possible. Some of the specific problems in this category included lead fracture, loss of capture, inappropriate sensing, and extra-cardiac stimulation.

Post-implantation risks. Data from 13 studies were used to assess post-implantation risks with CRT (Table 14 end of chapter). Over a median 6 months of followup, mechanical malfunction of the CRT device was noted in 6.7% (95% CI 5.4% to 8.2%) of successful implants. On sensitivity analysis, assuming any studies that failed to report this outcome had zero occurrences, this rate fell to 4.4% (95% CI 3.6% to 5.4%). Lead dislodgment occurred in 8.5% (95% CI 7.4% to 9.9%) of patients, with no differences in those studies using specially designed left ventricular leads (this estimate was reduced to 8.3%, 95% CI 7.1% to 9.6% on sensitivity analysis). Post-implantation infection (most commonly in the device pocket) occurred in 1.4% (95% CI 0.8% to 2.3%) of patients (reduced to 0.9%, 95% CI 0.5% to 1.4%, with sensitivity analysis). Arrhythmias attributed to the CRT device occurred in 1.7% (0.8% to 3.4%) of patients during followup.

## Decision Analysis

### Effectiveness of Medical Therapy

Expanding on the results from our systematic review outlined above, annual event rates were calculated (median followup time was 22.8 weeks in these trials). The annual risk of death was mean 24.3% (95% CI 20.0% to 29.2%) and the annual risk of heart failure hospitalization was 56.0% (95% CI: 47.6% to 66.2%).

### Effectiveness of Cardiac Resynchronization Therapy

Based on the results of the systematic review, annual event rates were calculated for patients with NYHA Class III heart failure randomized to CRT. The relative risks were: all-cause death 0.75 (95% CI: 0.60 to 0.93) and CHF hospitalizations 0.68 (95% CI: 0.41 to 1.12).

### Cost-Effectiveness of Cardiac Resynchronization Therapy

In patients with NYHA Class III heart failure, medical therapy had median 2.68 (interquartile range, IQR=2.49, 2.85) discounted quality-adjusted life years and median $34,700 (IQR= $31,100 to $38,100) lifetime costs (Table 15). Cardiac resynchronization had median 3.03 (IQR= 2.82 to 3.27) discounted quality-adjusted life years and median $67,600 (IQR= $62,000 to $73,800) lifetime costs. Cardiac resynchronization was associated with an incremental cost of median $90,700 (IQR= $69,500 to $124,900) per additional quality-adjusted life year. Data points from Monte Carlo simulation illustrate that compared to medical therapy, CRT is consistently associated with a survival gain and an additional cost (Figure 14). The cost-effectiveness acceptability curve illustrates that the probability that CRT is cost-effective relative to medical therapy alone is less than 59%, given a maximum willingness-to-pay for a quality-adjusted life year of $100,00 (Figure 15).

Table 15. Potential cost-effectiveness of cardiac resynchronization therapy

| Discounted Quality-Adjusted Life Years | Discounted Lifetime Cost | Incremental Cost-Effectiveness
| (QALYs), Median (Interquartile Range) | ($)*, Median (Interquartile Range) | ($/QALYs), Median (Interquartile Range)
Medical Therapy | 2.68 (2.49, 2.85) | $34,700 ($31,400, $38,100)
Cardiac Resychronization Therapy | 3.03 (2.82, 3.27) | $67,600 ($62,000, $73,800) | $90,700 ($69,500, $124,900)

* 2003 U.S. $ rounded to nearest hundred

Figure 14. Distribution of Incremental Costs versus Incremental Effects for Cardiac Resynchronization versus Medical Therapy

Figure 15. Cost-Effectiveness Acceptability Curve

### Variability Analyses

The incremental cost-effectiveness of CRT was sensitive to reasonable changes in values for several variables including relative risk of either death or hospitalization with CRT, probability of death during either lead failure or battery replacement, and costs of either device insertion or battery replacement (Table 3). Also, if CRT were associated with greater health-related quality of life than medical therapy, then the incremental cost-effectiveness of CRT was reduced (details available from authors).