# Methods

## Methods for the Systematic Reviews

### Literature Search

A medical librarian identified relevant databases and developed search strategies based on the following terms: biventricular pacing, biventricular pacer, biventricular stimulation, BiV, congestive heart failure, CHF, chronic heart failure, artificial cardiac pacing, heart diseases, chronic cardiac failure resynchronization therapy, dual-chamber pacing, cardiac resynchronization, Medtronic, InSync, ELA medical, randomized controlled trial, controlled clinical trial, meta-analysis, multi-center trial, safety, risk, adverse effects, side effects, harm, etiology, aetiology, contraindications, causation, causality, predict.

These search terms were adapted appropriately to search the following electronic resources: Cochrane Heart Group Trial Registry, Cochrane Library, EMBASE, International Pharmaceutical Abstracts, MEDLINE, PubMed, Web of Science, and Trial Registries (http://www2.umdnj.edu/~shindler/trials/trials a.html; http://www.nhlbi.nih.gov/index.htm; http://www.controlled-trials.com/;clinicaltrials.gov; http://www.update-software.com/National/; http://www.centerwatch.com/search.asp; and http://www.cardiosource.com). The detailed search strategies can be located in Tables A-1 to A-16, which are available on the AHRQ web site.

In addition, the investigators contacted the primary authors of key studies, sought Food and Drug Administration (FDA) reports, and reviewed the reference lists of all included articles. Additional unpublished data were also sought from the companies that make biventricular devices: Medtronic Inc., Guidant Corporation, and ELA Medical. The search was not limited by language or publication status and is considered up-to-date to June 2003.

### Selection and Inclusion

The librarian screened the initial search results to eliminate all duplicates. Following this, we used a two-step eligibility and selection process. First, two heart failure clinicians (JE, FM) independently screened all titles and abstracts to determine if an article met the general inclusion criteria (i.e., clinical trial, biventricular, dual chamber or multisite pacing, resynchronization therapy, human, symptomatic heart failure). Each article was rated as ‘include’, ‘exclude’, or ‘unclear’. The full text of all articles marked as ‘include’ or ‘unclear’ were retrieved. Second, two teams of physicians (JE and FM, and BR and TK) independently assessed the studies using specific inclusion and exclusion criteria for the efficacy and safety reviews, respectively (Table 2). Standard inclusion forms were used for this purpose (Tables B-1 and B-2, available on the AHRQ web site). Disagreements were discussed between reviewers until consensus on inclusion was reached. If needed, the investigators contacted the authors to clarify that individual publications reported on discrete patients. In cases of multiple publications involving the same or a portion of the same patients, the article with the most complete data was selected.

Table 2. Inclusion/exclusion criteria for review on cardiac resynchronization therapy

Criterion | Efficacy review | Safety review
Study Design | Include: RCT (parallel or crossover) > 2 weeks duration. | Include: RCT (parallel or crossover) or non-RCT (e.g., registry data, prospective cohort, FDA document, etc.) > 2 weeks duration.
| Exclude: non-RCTs, acute physiological studies, studies not involving human subjects | Exclude: acute physiological studies, studies not involving human subjects
Participants | Include: symptomatic CHF (NYHA Class ≥ II), decreased LVEF, prolonged QRS. Must be receiving stable optimal drug therapy | Include: symptomatic CHF (NYHA Class ≥ II), decreased LVEF, prolonged QRS. Must be receiving stable optimal drug therapy
Intervention | Treatment with active CRT (also called BVP, multi-site pacing, dual chamber pacer) compared to either placebo pacing or uni-ventricular pacing or optimal drug therapy | Treatment with active CRT (also called BVP, multi-site pacing, dual chamber pacer). Comparison group not necessary
Outcome measures | Mortality (all-cause, CHF, sudden cardiac death, non-cardiac), CHF hospitalizations, 6MWT, NYHA class, QOL | Peri-implant mortality, successful implant rate, risks of /during implantation, risks following implantation

BVP = biventricular pacing; LVEF = left ventricular ejection fraction; NYHA = New York Heart Association; QOL = quality of life; RCT = randomized controlled trial; 6MWT = six-minute walk test.

### Quality Assessments

Efficacy review. The methodological quality of RCTs was assessed independently by two reviewers (JE, CS) using two quality assessment methods. First, allocation concealment was assessed as adequate, inadequate, or unclear. Second, a five-point scoring system validated by Jadad^58^ was used to assess randomization, double blinding, and reporting of withdrawals and dropouts (Table B-3). In addition, the funding source and whether authors reported use of intention-to-treat analysis were noted. Discrepancies were resolved through discussion between the two reviewers.

Safety review. Studies included in the safety review were assessed for quality independently by two reviewers (CS, LH) using a partially validated checklist developed by Downs and Black.^59^ The checklist includes 28 questions evaluating five criteria (Table B-4). These five criteria are: Reporting (10 questions, total score 11), External validity (three questions, total score 3), Internal validity - bias (seven questions, total score 7), Internal validity - confounding (six questions, total score 6) and Power (two questions, total score 2). Decision rules regarding application of the tool were developed a priori through discussions with a cardiologist and a methodologist. Discrepancies in quality assessment were resolved through discussion.

### Data Extraction

Data were extracted using standard forms (Tables B-5 and B-6) designed for either RCTs (efficacy and safety reviews) or cohort studies (safety review) and entered into an Excel spreadsheet. Data were extracted by one reviewer (JE, CS, NW, or LH) and checked for accuracy and completeness by a second (JE, NW, or CS). Extracted data included study characteristics, inclusion/exclusion criteria, baseline drug use, characteristics of participants, procedural data, and outcomes. Efficacy outcomes included mortality (all cause as well as CHF death, sudden cardiac death, non-cardiac death) and time to death; CHF hospitalizations, six-minute walk test, NYHA class, quality of life, peak oxygen consumption, left ventricular ejection fraction, mitral regurgitation jet area, ECG and echocardiogram results. Safety outcomes included risks during implantation (death, lead misplacement, device-related malfunctions, procedural complications, implant tools, heart function, and patient complaints), risks following implantation (mechanical malfunction, lead dislodgment, infection, pain), and successful implant rate.

### Data Analysis

Efficacy review. The following imputations and manipulations were performed to form useable data. Standard errors were converted into standard deviations. Graph extraction was performed using Corel Draw 9.0 (Vector Capital, San Francisco, California) for time to death in the COMPANION trial.^60^ Means were approximated by medians, and 95% empirical intervals were used to calculate approximate standard deviations for the MIRACLE trial.^61^ Change from baseline data was used wherever possible for continuous data (PATH CHF^62^ being the exception); however, since correlations between baseline and endpoint data were never reported, a correlation of 0.5 was assumed^63^ to calculate the appropriate standard deviation for change from baseline data. Change from baseline and endpoint data were combined; both entities estimate differences between treatment groups. Efficacy results were extracted rather than intention-to-treat results when provided.

Numerical results were meta-analyzed primarily in Stata 7.0;^64^ metagraphs were generated using S-plus 6.0.^65^ For dichotomous results (e.g., CHF hospitalizations), the review included relative risks (RR) for each individual study as well as a pooled result among those studies that could be combined. Additionally, risk differences were considered where zero total events occurred in both groups. Increments of one or more across functional classification (e.g., from Class III to Class II) were considered a dichotomous outcome. For continuous variables, mean differences (e.g., six-minute walk test) were calculated for separate studies and the weighted mean difference (WMD) for the pooled estimate. Time-to-event data (i.e., death) were summarized by the log hazards ratio;^66^ Kaplan Meier curves were generated. An individual patient dataset for this analysis was constructed using summary monthly mortality tables in the trial manuscripts. The Log Rank test assessed for treatment group differences across curves. All results were reported with 95% confidence intervals (CIs) where reasonable.

Due to the differences expected between studies (particularly in control group therapies), we decided a priori to combine results primarily using random effects model;^67^ fixed effects models were considered in sensitivity analyses. Statistical heterogeneity was assessed by the Chi-square test; a conservative level of significance (p<0.10) was considered heterogeneous.^68^ Also, heterogeneity was quantified and appropriated using the I-squared statistic.^69^ Inclusion of studies with active control arms^62,^ ^70^ was assessed in sensitivity analyses. Relevant direct subgroup comparisons were summarized, including effects of CRT in patients with more severe heart failure symptoms (NYHA Class III or IV). Implantable cardioverter defibrillators (ICDs) were considered in an indirect subgroup comparison using meta-regression.

Estimates of carryover effect were extracted from crossover designs. Only period one data were used for irreversible outcomes (i.e., death and CHF hospitalizations). Standard errors for crossover WMD were calculated according to Curtin.^71^

Safety review. Numerical results were meta-analyzed primarily in S-plus 6.0. Risks were simply pooled and all results were reported with 95% CIs. Statistical heterogeneity was assessed by the Chi-square test; p<0.10 was considered heterogeneous.^68^ Also, heterogeneity was quantified and appropriated using the I-squared statistic.^69^ Exclusion of NYHA class II data and studies with active control arms^62,^ ^70^ was assessed in sensitivity analyses but is not reported here.

The possibility that reports may have been less judicious in reporting adverse events that did not occur was considered. Sensitivity analyses were performed where studies (randomized controlled or cohort) did not report a particular risk (e.g., death); zero adverse events were assumed for these studies. In addition, some implantation risks were reported by event and not by patient. This non-independence was small and would not be expected to affect results importantly.

## Methods for the Decision Analysis

The purpose of the decision analysis was to provide policy makers with a better understanding of the role of this new health technology for the treatment of congestive heart failure from a healthcare system perspective. The specific objectives were: 1) to estimate the long-term effects and costs of the use of cardiac resynchronization compared with medical therapy alone in patients with symptomatic congestive heart failure and reduced left ventricular ejection fraction, and 2) to calculate the incremental cost-effectiveness of cardiac resynchronization relative to medical therapy alone. The decision model compares the lifetime effects and costs of two treatment strategies for congestive heart failure: cardiac resynchronization in addition to medical therapy vs. medical therapy alone.

### Structure of the Decision Model

The primary analysis considered patients with NYHA III heart failure and prolonged QRS duration. This analysis considered the lifetime horizon, as recommended.^72^ A state-transition Markov model compared costs and outcomes of congestive heart failure treated by CRT and medical therapy vs. medical therapy alone. A cycle length of one month was used.

During each cycle, patients who received medical therapy could die of unrelated causes, die of cardiovascular disease, be hospitalized for heart failure, or remain stable (Figure 1 end of chapter). Patients who underwent biventricular pacemaker insertion could die during initial implantation of the device, experience lead infection, lead failure, or battery failure, or experience any of the health states associated with medical therapy for heart failure.

Figure 1. Decision model for medical therapy versus cardiac resynchronization therapy for heart failure

Decision analyses were performed with DATA Pro software (TreeAge Software Inc., Williamstown, Massachusetts) and Excel 2000 software (Microsoft Inc., Redmond, Washington). Statistical analyses were performed with S-Plus (Insightful Inc., Seattle, Washington).

### Input Data

Survival and Hospitalization. Baseline probabilities of adverse events, the probabilities of cardiovascular death, arrhythmic death, heart failure death, hospitalization for heart failure, and adverse effects associated with the therapy options, as well as estimates of life expectancy associated with each therapy, were derived from the meta-analyses described above. Nine trials were included in the efficacy analysis: Comparison of Medical Therapy, Pacing, and Defibrillation in Chronic Heart Failure (COMPANION),^60^ CONTAK CD,^73^ Garrigue et al.,^70^ Multicenter InSync Randomized Clinical Evaluation (MIRACLE),^61^ Multicenter InSync Randomized Clinical Evaluation ICD (MIRACLE ICD),^36^ Multisite Stimulation in Cardiomyopathies Sinus Rhythm (MUSTIC SR),^74^ Multisite Stimulation in Cardiomyopathies Atrial Fibrillation (MUSTIC AF)^75^, the Pacing Therapies for Congestive Heart Failure trial (PATH CHF)^62^ , and the RD-CHF Trial (Leclerq C, personal communication, December 2003).

The rate of events observed among patients randomized to medical therapy was annualized by using an exponential approximation.^76,^ ^77^ Transition probabilities incorporated into the Markov Model were adjusted for the cycle length. Pooled relative risks were calculated by using the Dersimonian and Laird random effects model.^67^

The base case analysis considered only the effect of CRT on all-cause mortality since it is difficult to subclassify causes of death in patients with cardiovascular disease. Cardiac and non-cardiac deaths were only considered in secondary analyses that accounted for the patient age at implantation (ie. differences in mortality due to unrelated causes).

Quality of Life. The health-related quality of life of patients with heart failure was estimated by eliciting utilities, since current standards suggest use of such outcome measures, and the relative cost-effectiveness of some cardiac therapies is sensitive to the magnitude of the difference between the utilities associated with either treatment.^78,^ ^79^ Since the purpose of the decision analytic model was to consider an intervention in the context of resource allocation among different types of interventions, the use of a generic source of preferences was used as recommended.^78^ A convenience sample (n=90) of members of the general public was recruited. Inclusion criteria were: fluent in English, provision of informed consent, age greater than 40, and no underlying cardiac disease. Consenting subjects estimated utilities for standardized health state descriptions by using the standard gamble technique.^80^ Four health states were considered: NYHA functional class II, III, IV, and congestive heart failure severe enough to require hospitalization. Hypothetical scenarios describing what one would typically feel and experience if living with each of these health states were developed with input from an expert panel based on descriptors from the Health Utilities Index.^81^

Costs. The economic analysis was conducted from a health care perspective, including costs of hospitalization, procedures, ambulatory visits, medications, and laboratory tests. Costs are expressed in 2003 American dollars (Table 3, end of chapter). The costs of a CRT device were based on a survey of manufacturers' list prices. Physician costs related to CRT implantation were based on Current Procedural Terminology codes (http://www.naspe.org/pdf_files/cpt_coding_form_0304.pdf - accessed on June 15, 2003). The costs of hospitalizations associated with congestive heart failure were based on estimates derived from a cohort study of health resource use by patients participating in a previous randomized trial of medical therapy for heart failure.^82^ All costs were adjusted for inflation by using the U.S. Consumer Price Index (http://stats.bls.gov/cpi accessed on May 30, 2003).

Table 3. Input data for decision analysis on cardiac resynchronization in patients with NYHA Class III heart failure

Variable | Best Estimate | Lowest | Highest | Distribution | Threshold Value | References
Age of patient (yr.) | 60 | 50 | 70 | Normal | n/a | Assumed
Annual probability of cardiac death without CRT (%) | 24.3 | 20.0 | 29.2 | Beta | n/a | This systematic review
Relative risk of death with CRT | 0.75 | 0.60 | 0.93 | Normal | 0.78 | This systematic review
Annual probability of heart failure hospitalization without CRT (%) | 56.0 | 47.6 | 66.2 | Beta | n/a | This systematic review
Relative risk of heart failure hospitalization with CRT | 0.68 | 0.41 | 1.12 | Normal | 0.85 | This systematic review
Annual rate of cardiac death without CRT (%) | 20.3 | 15.1 | 27.0 | Beta | n/a | This systematic review
Relative risk of cardiac death with CRT | 0.60 | 0.36 | 1.01 | Normal | n/a | This systematic review
Relative risk of death due to unrelated causes with CRT | 1.0 | 0.9 | 1.1 | Triangular | n/a | Assumed
Annual rate of lead infection (%) | 2.0 | 1.1 | 3.2 | Beta | n/a | This systematic review
Annual rate of lead failure (%) | 13.7 | 11.7 | 16.1 | Beta | n/a | This systematic review
Annual rate of battery replacement (%) | 10.8 | 8.7 | 13.4 | Beta | n/a | This systematic review
Probability of death during insertion (%) | 0.4 | 0.2 | 0.7 | Beta | n/a | This systematic review
Probability of death during lead infection (%) | 1.0 | 0 | 10 | Beta | n/a | Assumed
Probability of death during lead failure (%) | 1.0 | 0 | 10 | Beta | 7.3 | Assumed
Probability of death during battery replacement (%) | 1.0 | 0 | 10 | Beta | 8.6 | Assumed
Utility of NYHA II heart failure | 0.94 | 0.84 | 0.99 | Triangular | n/a | Survey
Utility of NYHA III heart failure | 0.84 | 0.71 | 0.98 | Triangular | n/a | Survey
Utility of NYHA IV heart failure | 0.74 | 0.58 | 0.91 | Triangular | n/a | Survey
Utility of hospitalization for heart failure | 0.57 | 0.48 | 0.80 | Triangular | n/a | Survey
Relative Utility of heart failure with CRT | 1.0 | 0.9 | 1.1 | Triangular | n/a | Assumed
Duration of hospitalization for CRT implantation | 5 days | 0 | 1 mos. | Triangular | n/a | Assumed
Duration of hospitalization for lead failure | 5 days | 0 | 1 mos. | Triangular | n/a | Assumed
Duration of hospitalization for lead infection | 5 days | 0 | 1 mos. | Triangular | n/a | Assumed
Duration of hospitalization for battery replacement | 5 days | 0 | 1 mos. | Triangular | n/a | Assumed
Discount rate for future costs and effects | 3% | 0% | 10% | Triangular | n/a | Gold^78^
Cost of CRT insertion * | $33,495 | $16,747 | $50,242 | Triangular | $41,000 | Survey
Cost of CRT, per mo. | $771 | $385 | $1,216 | Triangular | n/a | Owens^92^
Cost of hospitalization for lead infection | $30,997 | $15,499 | $46,496 | Triangular | n/a | Owens^92^
Cost of hospitalization for lead failure | $30,997 | $15,499 | $46,496 | Triangular | n/a | Owens^92^
Cost of battery replacement | $28,835 | $14,417 | $43,252 | Triangular | $38,000 | Owens^92^
Cost of heart failure hospitalization | $15,427 | $10,660 | $20,193 | Normal | n/a | Kaul^82^

CRT=cardiac resynchronization therapy; NYHA= New York Heart Association

* Cost estimates in U.S. dollars

Assumptions. We made several assumptions about the costs and effects of CRT. First, unit costs of complications related to CRT are identical to those for implantable cardioverter defibrillators. Second, unit costs of heart failure therapy (ie. costs of out patient or in patient care) were otherwise identical between medical therapy and CRT. Third, the incidence of complications associated with CRT was constant over time from implantation. Since the duration of study followup in each trial was relatively short and the incidence of adverse effects observed in the randomized trials was higher than is generally accepted for implantable cardioverter defibrillator use (which may reflect relative inexperience with biventricular pacemakers),^83^ the primary analysis assumed that the annual probability of each of lead infection, lead failure or mechanical malfunction was 3.0% (range 0% to 10%). We also assumed that any mechanical malfunction of the device required battery replacement with consequent costs and consequences. Fourth, uncomplicated CRT had identical health-related quality of life as that of medical therapy. Fifth, the utility for hospitalization was identical, regardless of the reason for hospitalization. The morbidity of hospitalization was incorporated into the model by assigning the utility for hospitalization to it's duration, and assigning the utility for the health state prior to hospitalization to the remainder of the cycle. Finally, age-specific mortality due to unrelated causes was based on life tables.^84^

An intervention that was more effective and less costly than the other was considered to be “dominant” and hence preferred to the alternative.

### Uncertainty and Variability Analyses

The analysis distinguished between parameter uncertainty (i.e., variation in costs and effects due to sampling and measurement error) and variability (i.e., heterogeneity in costs and effects between groups of patients with systematic differences in cost or effects). Uncertainty was assessed by using 10,000 probabilistic Monte Carlo simulations.^85,^ ^86^ Empirical cost variables were assigned log-normal distributions. Empirical probability variables were assigned beta distributions.^85^ Variables without a known distribution form (i.e., those with assumed values, or those with values based on a range of published reports) were assigned triangular distributions.^87^ Since there is no absolute cost-effectiveness criterion,^88^ the results of the Monte Carlo simulations were illustrated as a scatter plot of incremental effects (in quality-adjusted life years) versus incremental costs. In such a plot, the incremental cost-effectiveness ratio is represented by the slope of incremental costs to incremental effects. The uncertainty in costs and effects was also illustrated as a cost-effectiveness acceptability curve. An acceptability curve is a conditional probability plot showing the proportion of the observed incremental cost-effectiveness density that lies below a threshold ratio, which represents the monetary value of a unit of health gain. The plot is conditional on the threshold ratio, and therefore the decision maker can interpret the data in light of their threshold willingess to pay for the incremental health outcome.

Variability was assessed by using sensitivity analyses as follows. We substituted the upper and lower limits of the value of each variable in the decision model while holding all other values constant (Table 3).^89,^ ^90^ For empirical variables, these limits were the 95% confidence limits for each variable. For assumed variables (e.g., cost of cardiac resynchronization and discount rate), these limits were based on reasonable possible limits (i.e., ±50%). Threshold analyses identified the value of each variable across its range, if any, at which one should be indifferent between medical therapy or CRT (i.e., the incremental costs per quality-adjusted life year was $100,000).^90^

Multiway sensitivity analyses were also performed. Since the effectiveness of both interventions may be correlated, we varied simultaneously the probability of arrhythmic death with medical therapy, and relative risk of arrhythmic death with CRT. Since the rate of adverse effects observed in the randomized trials was higher than is generally accepted for implantable cardioverter defibrillator use,^83^ the incidence of device-related adverse effects observed in the trials was substituted into the model.

A structural sensitivity analysis considered the relative risks of cardiovascular death (heart failure death and sudden cardiac death) disaggregated with CRT versus medical therapy alone (Figure 2, end of chapter). Since it is difficult to classify cardiovascular deaths as arrhythmic or non-arrhythmic,^91^ the pooled relative risk of arrhythmic death and non-arrhythmic death were based on retrospective subgroup analyses of data observed in the randomized trials of CRT. There is ongoing debate in the clinical community about whether CRT increases the risk of sudden cardiac death.

Figure 2. Markov Model of Resynchronization Therapy of Heart Failure

Finally, subgroup analyses considered the incremental cost-effectiveness of CRT versus medical therapy alone for patients with NYHA II or NYHA IV heart failure by substituting the appropriate health-related quality of life weight.

## Peer Review

We asked 27 external people to peer review a draft of the report—consisting of the two completed reviews and the decision analysis. Nine agreed to do so, and we received comments from five of them. Authors considered their comments, as well as 6 anonymous peer reviewers from the Annals of Internal Medicine, and amended the analyses and document accordingly. Peer reviewers are listed in Appendix D, available on the AHRQ web site (except of course the anonymous peer reviewers from the Annals of Internal Medicine).