# Introduction and Background

## The Problem of Congestive Heart Failure

Congestive heart failure (CHF) leads to significant morbidity and mortality; in 2001 it accounted for almost one million hospitalizations in the United States (as the most responsible diagnosis) and $24.3 billion in direct and indirect costs.^1^ CHF is the fastest growing cardiovascular diagnosis in North America: the community prevalence is estimated at 0.4% to 2.4% in adults,^1–4^ with the incidence approaching 10 cases/1000 in people over 65 years of age.^1^ Indeed, the lifetime risk of developing CHF is estimated at 20% in North America.^5^ Despite many advances in diagnosis and therapy over the past two decades, heart failure carries a poor prognosis (30% to 50% mortality rate at 1 year), which has changed little over that time frame.^1,^ ^6^

Patients with CHF may be classified on the basis of their functional status using the New York Heart Association (NYHA) Classification. In this system, CHF patients without limitations of physical activity (i.e., ordinary physical exertion does not cause fatigue, palpitations, dyspnea, or chest discomfort) are classified as having NYHA Class I disease. CHF patients who develop fatigue, palpitations, dyspnea, or chest discomfort with ordinary physical activity (defined as walking two blocks or climbing two flights of stairs) are classified as having NYHA Class II disease. Those patients who are comfortable at rest but develop symptoms on less than ordinary activity are categorized as having NYHA Class III disease. Finally, CHF patients who have symptoms at rest or with minimal activity are classified as having NYHA Class IV disease.

Attempts to reduce mortality in heart failure are directed at the two main ways in which death occurs: sudden cardiac death (electrical failure) and progressive heart failure (mechanical failure).^7^ Sudden cardiac death accounts for more deaths than progressive “pump” failure in patients with NYHA Class I or II heart failure; on the other hand, progressive heart failure is the predominant cause of death in those with NYHA Class III or IV symptoms.^8^ It is important to emphasize that not all therapies that improve functional outcomes (such as symptoms, quality of life, ejection fraction, and other hemodynamic measurements) in CHF patients confer survival benefits.^9^ Thus, it is essential that any novel therapies in patients with CHF be evaluated for their impact on clinically important outcomes such as death or hospitalization.

Heart failure is a clinical syndrome characterized by specific symptoms and, in most (but not all) cases, accompanied by a depressed ejection fraction.^10^ Coronary artery disease is the cause of heart failure in two-thirds of North American and European patients, with hypertension, valvular dysfunction, viral myocarditis, idiopathic dilated cardiomyopathy, and other diseases causing the remainder.^11^ Identification of modifiable risk factors in CHF has lead to the development of treatment options for heart failure including the standard pharmacological, non-pharmacological, and electrically based therapies currently recommended in consensus guidelines for the care of patients with CHF.^10,^ ^12,^ ^13^

## Current Risk Factors and Markers in Congestive Heart Failure

Many prognostic risk factors have been established in CHF (Table 1). Well-validated risk factors for short- and long-term mortality include demographic factors such as older age and male gender;^14^ differing ethnic background (black patients have a higher mortality rate than white patients even after adjustment for important covariates);^15,^ ^16^ co-morbidities such as diabetes mellitus,^17^ anemia,^18^ and poor renal function;^19^ and physical examination findings such as a third heart sound and elevated jugular venous pressure.^20^ Biochemical values that predict mortality include decreased serum sodium,^21^ elevated aldosterone, angiotensin II, and arginine vasopressin,^22^ elevated brain natriuretic peptide,^23^ and elevated levels of other neurohormones.^24^ Other prognostic risk factors have been explored (such as genetic and echocardiographic markers) and are reviewed elsewhere;^25^ electrophysiologic prognostic factors are reviewed below.

Table 1. Prognostic risk factors in congestive heart failure

Demographics: | Electrophysiologic findings:
Older age | Ventricular arrhythmias
Male gender | Intraventricular conduction delay
Ethnic background (blacks have poorer outcomes than whites) | Atrial fibrillation T-wave alternans
Comorbidities:
Diabetes | Laboratory findings:
Anemia | Elevated norepinephrine/epinephrine
Renal failure | Low sodium
| Elevated creatinine
Clinical Assessment: | Elevated aldosterone
Advanced symptoms (NYHA Class III or IV) | Elevated B-type natriuretic peptide
Elevated jugular venous pressure | Elevated Tumor Necrosis Factor-alpha
Edema | Elevated InterLeukin-6
Third heart sound | Elevated endothelin-1
| Elevated angiotensin II
Hemodynamics: | Elevated renin
Lower left ventricular ejection fraction | Elevated troponin I/T
Lower right ventricular ejection fraction | Elevated arginine vasopressin
Elevated pulmonary capillary wedge pressure
Elevated pulmonary vascular resistance

Source: adapted from Eichhorn EJ. Prognosis determination in heart failure. Am J Med 2001;110 (Suppl 7A);14S–36S^25^ NYHA=New York Heart Association

## Current Therapeutic Strategies for Congestive Heart Failure

Current therapy for congestive heart failure incorporates a number of strategies to enhance the quality of life, improve exercise tolerance, and reduce morbidity and mortality. In the past two decades, advances in heart failure management have arisen from randomized clinical trials of medications, non-pharmacologic interventions (exercise training, care delivery systems), electrophysiologic procedures and devices, and surgery including cardiac transplantation.

### Pharmacologic Management

Afterload reduction with the combination of isosorbide dinitrate and hydralazine was one of the first pharmaceutical combinations tested and used to treat heart failure. It achieved a relative risk reduction in mortality of approximately one third when compared to placebo.^26,^ ^27^ While enalapril (an angiotensin-converting enzyme [ACE]) inhibitor was subsequently proven to be more effective than hydralazine/isosorbide dinitrate, the combination remains useful for management of those heart failure patients intolerant of ACE inhibitors or angiotensin-receptor blockers (ARB), and in those with advanced renal insufficiency.^10^

ACE inhibitors were the first medications to show a reduction in mortality in advanced congestive heart failure patients (those with NYHA Class IV symptoms), with a relative risk reduction for the enalapril group (versus placebo) of 40% at 6 months.^28^ Since then, 33 other randomized placebo-controlled trials^29^ of ACE inhibitors have confirmed substantial benefits (in the order of 25% to 35% reductions in mortality and 27% to 33% reductions in hospitalization rates) in patients with all classes of heart failure (even asymptomatic patients with reduced ejection fraction). ACE inhibitors are now the cornerstones of treatment for systolic left ventricular dysfunction with or without symptoms.^30^

Beta-blockers are the second choice in the pharmacologic treatment of systolic dysfunction. Twenty-two randomized controlled trials have demonstrated consistent benefits in reducing mortality (relative risk reduction 35%) and morbidity (relative risk reduction 36% in hospitalization),^31^ and improving NYHA class and quality of life.^32^

Angiotensin-receptor blockers have been demonstrated to reduce a combined endpoint of morbidity and mortality by 13% when added to ACE inhibitor therapy and have an indication as primary therapy for heart failure in ACE-inhibitor intolerant patients, either alone or with beta-blockers. The reduction in hospitalization alone is 27% when added to an ACE inhibitor. Caution is urged when patients are concomitantly taking an ACE-inhibitor and beta-blocker, as no additional benefit was seen in a group of patients on all three agents.^33,^ ^34^

Aldosterone blockade (with spironolactone or eplerenone) is associated with relative risk reductions of 15% to 30% in mortality for patients with NYHA Class III/IV symptoms and an ejection fraction <35%,^35^ or patients with an ejection fraction <40% and a recent myocardial infarction.^36^ These benefits were largely due to reduced rates of sudden cardiac death. Furthermore, both agents are associated with 27% to 35% relative risk reductions in heart failure hospitalizations.^35,^ ^36^ Digoxin has also been shown to reduce hospitalization rates, but without significant impact on mortality in patients with CHF.^37^

### Non-Pharmacologic Management

Lifestyle modification is important in the management of symptomatic CHF patients. The importance of avoiding non-steroidal anti-inflammatory drugs has been highlighted in numerous studies where use of anti-inflammatory drugs has been associated with a two- to four-fold increase in hospitalizations for acute heart failure.^38,^ ^39^ Non-compliance with sodium restriction has been identified as the cause of up to 22% of hospitalizations for CHF, highlighting the importance of dietary modification for these patients.^39^ Finally, addressing concomitant risk factors for underlying coronary artery disease (dyslipidemia, tobacco use, hyperglycemia) is important in the secondary prevention of myocardial ischemia in CHF patients. Another non-pharmacologic strategy includes specialty clinics that provide a multidisciplinary disease management approach to this complex disease.^40^ While a systematic review of 11 randomized trials showed that patients managed in specialized multidisciplinary heart failure clinics had better processes of care and outcomes,^41^ it is unclear whether these benefits can also be expected with “specialist” physicians operating outside the bounds of a multidisciplinary clinic. Exercise training can also result in substantial improvements in functional status for patients with CHF, but existing studies have not reported consistent results or have involved regimens that are not practical in an ambulatory care setting.^42,^ ^43^

### Surgical Management

There are some surgical interventions for heart failure that may also improve survival when directed to the appropriate patients at risk. Left ventricular assist devices can improve short-term cardiac function and provide a bridge to cardiac transplantation for appropriately selected NYHA Class IV patients. Indeed, they have recently even been approved as destination therapy for patients with end-stage heart failure.^44^ Valvular repair or replacement, revascularization of ischemic myocardium,^45^ and other surgical approaches to heart failure have been proven or are under investigation to improve both survival and quality of life in selected patients. Finally, cardiac transplantation is effective. However, this is offered to fewer than 2500 individuals per year in the United States and is not a solution for the vast majority of heart failure patients.

Unfortunately, even with the best care using optimal combinations of these non-pharmacologic, pharmacologic, and surgical approaches, the mortality rate remains high and quality of life is usually poor for patients with CHF. As an example, in a specialized heart failure clinic where 86% of patients are on ACE inhibitors or ARB, 46% are on a beta-blocker, and 45% of patients seen since 1999 are on spironolactone, the mortality rates are still 27%, 43%, and 74% at 1, 2, and 5 years.^46^

Clearly, there is a need for additional treatment strategies in CHF that can improve function, diminish symptoms, reduce hospitalizations, and/or increase survival. Recent studies have shown that cardiac resynchronization therapy (CRT) with biventricular pacemakers offers improvements in quality of life, NYHA class, and six-minute walk test results, but have yet to demonstrate a conclusive mortality benefit. Implantable cardioverter defibrillators (ICDs) do not improve functional outcomes, but do provide a substantial mortality benefit (through the prevention of sudden cardiac death) in patients with a history of ventricular arrhythmias or at high risk due to ischemic substrate and poor ejection fraction.^47^

## Pacing in CHF

Electrical conduction disturbances are common in heart failure, including atrial or ventricular dysrhythmias, atrioventricular conduction delay, and inter- and intraventricular conduction disturbances. The QRS duration is used as an electrical marker for mechanical activation. In an Italian registry of heart failure patients, left bundle branch block was present in 25% of patients and was associated with an increased one-year mortality (Hazard Ratio 1.70, [95% Confidence Interval [CI] 1.41 to 2.05]).^48^ Intraventricular conduction delay (exact width of QRS not defined) was present in 25% to 50% of the patients in a specialty clinic analysis and was associated with increased mortality after adjustment for other important covariates (Hazard ratio 1.84, 95% CI 1.22 to 2.76).^49^ In a third study, the 33% of patients with a QRS duration of >120 msec had the worst survival.^50^

The presence of either left bundle branch block or intraventricular conduction delay are associated with physiological changes in cardiac function, including a reduction in ventricular dP/dt, prolonged duration of mitral regurgitation, and abnormal or paradoxical ventricular septal wall motion. Delay in electrical conduction results in increased duration of mitral regurgitation or the opportunity for pre-systolic mitral regurgitation to develop. There is an increase in the overall ventricular contraction time due to delayed activation of the left free wall and together this results in mechanical dyssynchrony and a reduction in cardiac output.

Original attempts at pacing in heart failure using right-sided dual-chamber atrioventricular (AV) sequential devices produced short-term physiological improvements,^51^ but subsequent randomized trials failed to demonstrate a functional or mortality benefit in CHF.^52^

Biventricular pacing (BVP), or CRT, involves pacing simultaneously in the right atrium, right ventricle, and left ventricle. It was first tried as a short-term bridge after cardiac surgery; subsequent physiological studies demonstrated improved cardiac function with reductions in both pulmonary capillary wedge pressure and myocardial oxygen use when compared to dobutamine.^53–56^ Since the first attempts at synchronized atrial-biventricular pacing by Cazeau et al.^57^ many mechanical improvements in the devices, refinements of the implantation technique, and advances in patient selection have occurred.

## Objectives of this Review

The benefits of CRT in congestive heart failure have now been tested in several randomized clinical trials, but due to small numbers of events, no definitive mortality benefit has been demonstrated. Furthermore, surrogate measures were used as the primary endpoint in many of these trials, and the impact of this potentially costly therapy cannot be estimated from the existing data. Through performing a systematic review and meta-analysis of these trials, we sought to determine if CRT reduces mortality (all-cause, progressive heart failure, sudden cardiac death), hospitalization rates, and/or improves functional outcomes and quality of life in patients with symptomatic CHF. We also sought to clarify the safety of these devices within clinical trials and when used in the non-trial setting. Finally, to clarify the effects of CRT on the healthcare system, we performed a decision analysis that incorporated safety, effectiveness, and cost data for biventricular pacemakers, taking into account other proven effective therapies in CHF (such as ACE inhibitors, beta blockers, aldosterone antagonists, digoxin, and multidisciplinary specialty clinics).

## Study Questions

The specific questions we attempted to address in this project were:

- In adult patients with symptomatic CHF, is CRT more effective than optimal medical care alone or univentricular pacing?
- Is the implantation of a CRT system safe for patients?
- What is the role of CRT in the treatment of CHF?
- Which patients with CHF would most likely benefit from CRT?
- What is the cost-effectiveness of CRT in patients with CHF?