# Appendix D: Technical Experts and Peer Reviewers

## Technical Experts

- William Abraham
- The Ohio State University, Columbus, OH

- Justin Ezekowitz
- University of Alberta, Edmonton, AB

- Padma Kaul
- University of Alberta, Edmonton, AB

- Terry Klassen
- University of Alberta, Edmonton, AB

- Finlay McAlister
- University of Alberta, Edmonton, AB

- Graham Nichol
- Ottawa Health Research Institute, University of Ottawa, Ottawa, ON

- Gerald Peden
- Independent Blue Cross

- Brian Rowe
- University of Alberta, Edmonton, AB

## Peer Reviewers

- Donald Casey
- Catholic Healthcare Partners, Cincinnati, OH

- Robert Kowal
- UT Southwestern Medical Center, Dallas, TX

- Robert Rea
- Mayo Clinic, Rochester, MN

- Bruce Wilkoff
- The Cleveland Clinic Foundation, Cleveland, OH

- Clyde Yancy
- St. Paul University Hospital / UT Southwestern Medical Center, Dallas, TX