# Appendix C: Evidence Tables

Evidence Table C-1. Inclusion criteria of randomized trials on CRT for CHF: Efficacy review

| Inclusion Criteria | | | | | | | | Exclusion Criteria
Trial name | NYHA class | LVEF | QRS | LVEDD | Meds required | | Sinus rhythm (%) | Other
| | | | | ACEi | BB
Abraham 2002^1^ MIRACLE | III or IV | <=35% | >=130 ms | >=55 mm | yes | yes | yes | 6MWT <=450 m; expected to remain stable | Had a pacemaker or defibrillator; had an indication for or contraindication against cardiac pacing; unstable angina; acute MI; cardiac ischemic event, or revascularization in past 3 mo.; atrial arrhythmia in past 1 mo.
Auricchio 2002^2^ PATH-CHF | III or IV | - | >=120 ms | - | no | no | yes | PR interval >=150 ms | Primary operable valvular heart disease (other than mitral or tricuspid regurgitation with clinical symptoms due to LV systolic HF); indication for conventional pacemaker or implantable cardioverter-defibrillator or other noncardiac conditions that could limit exercise capacity and life expectancy
Bristow 2003^3^ COMPANION Scientific Presentation 2003 | III or IV | <=25% | >=120 ms | >=60 mm | yes | yes | yes | > 18 yr.; PR > 150ms; diuretic; spironolactone; digoxin; Hx hospitalization <12 mo. > 1 mo. prior to enrollment; OPT for CHF | Meet indications for general ICD or antibradycardia pacing; chronic atrial tachyarrhythmias; MI or PTCA < 60 days; uncontrolled BP; unstable angina; have a tricuspid prothesis; expected to have transplant or life expectancy < 6 mo.
Cazeau 2001^4^ MUSTIC-SR | III | <35% | >150 ms | >60 mm | yes | no | yes | diuretics | Hypertrophic or restrictive cardiomyopathy; correctable valvulopathy; acute coronary syndrome or coronary revascularization in past 3 mo.; scheduled revascularization; severe obstructive lung disease; indication for an ICD
Garrique 2002^5^ | III or IV | < 40% | > 140 ms | >=60 mm | yes | yes | no | OPT for CHF; diuretics; chronic AF; HIS bundle ablation | < 18 or > 80 yr.; unstable angina < 2 mo. of start; acute MI < 6 mo.; angioplasty or CABG < 1 yr.
Guidant 2002^6^ CONTAK-CD FDA report | II, III or IV | <=35% | >=120 ms | - | yes | no | yes | Meet indications for ICD; diuretics and/or digoxin; >=18 yr. | Meet indications for antibradycardia pacing; refractory atrial tachycardia; require concomitant cardiac surgery; not suitable for the procedure
Leclercq 2002^7^ MUSTIC-AF | III | <35% | >200 ms | >60 mm | yes | no | no | diuretics; AF >3 mo.; requiring pacing (AV ablation or spontaneously); 6MWT <450 m | Hypertrophic or restrictive cardiomyopathy; correctable valvulopathy; acute coronary syndrome or coronary revascularization in past 3 mo.; scheduled revascularization; severe obstructive lung disease; indication for an ICD
Leclercq 2003 RD-CHF* Unpublished | III or IV | <=35% | >180 ms | N/a | N/a | N/a | N/a | N/a | N/a
Medtronic 2001^9^ MIRACLE-ICD FDA report | II, III or IV | <=35% | >=130 ms | >=55 mm | yes | no | no | ICD indication; =>18 yr.; previous MI; recurrent or sustained VT | Unstable angina; MI, CABG, PTCA, TIA or CVA in past 3 mo., indications for or contraindications against standard cardiac pacing; systolic BP <80 or >170mm; HR >140bpm; hepatic function >3 times upper limit of normal; primary valvular disease/rt heart valve, COPD; life expectancy <6 mo.

ACEi = angiotensin converting enzyme inhibitors; AF = atrial fibrillation; BB = beta blockers; BP = blood pressure; CABG = coronary artery bypass grafting; CHF = congestive heart failure; COPD = chronic obstructive lung disease; CVA = coronary vascular accident; FDA = Food and Drug Administration; HR = heart rate; HX = history; ICD = implantable cardioverter-defibrillator; LVEDD = left ventricular end diastolic diameter; LVEF = left ventricular ejection fraction; MI = myocardial infarction; NYHA= New York Heart Association class; OPT= optimal pharmacological therapy; PTCA= percutaneous trans cardiac angioplasty; 6MWT= 6 min. walk test; n/a = not available; TIA = transient ischemic attack; VT = ventricular tachycardia.

* detailed data not available for Leclercq 2003 (RD-CHF) at the time this report was prepared; information included in this report was obtained through personal communication with the author

Evidence Table C-2. Inclusion criteria of studies included in the safety review on CRT for CHF

| Inclusion Criteria | | | | | | | | Exclusion Criteria
Trial name | NYHA class | LVEF | QRS | LVEDD | Meds required | | Sinus rhythm (%) | Other
| | | | | ACEi | BB
Abraham 2002^1^ MIRACLE | III or IV | <=35% | >=130 ms | >=55 mm | yes | yes | yes | 6MWT <=450 m; expected to remain stable | Had a pacemaker or defibrillator; had an indication for or contraindication against cardiac pacing; unstable angina; acute MI; cardiac ischemic event, or revascularization in past 3 mo.; atrial arrhythmia in past 1 mo.
Auricchio 2002^2^ PATH-CHF | III or IV | | >=120 ms | | no | no | yes | PR interval >=150 ms | Primary operable valvular heart disease (other than mitral or tricuspid regurgitation with clinical symptoms due to LV systolic HF); indication for conventional pacemaker or implantable cardioverter-defibrillator or other noncardiac conditions that could limit exercise capacity and life expectancy
Bristow 2003^3^ COMPANION Scientific Presentation 2003 | III or IV | <=25% | >=120 ms | >=60 mm | yes | yes | yes | > 18 yr.; PR > 150ms; diuretic; spironolactone; digoxin; Hx hospitalization <12 mo. > 1 mo. prior to enrollment; OPT for CHF | Meet indications for general ICD or antibradycardia pacing; chronic atrial tachyarrhythmias; MI or PTCA < 60 days; uncontrolled BP; unstable angina; have a tricuspid prothesis; expected to have transplant or life expectancy < 6 mo.
Cazeau 1996^4^ | - | - | - | - | - | - | - | End stage CHF who refused or not eligible for transplant all had Hx of HD >=10 yr. and >=1 episode of pulmonary edema | No specific inclusion/exclusion criteria stated
Cazeau 2001^5^ MUSTIC-SR | III | <35% | >150 ms | >60 mm | yes | no | yes | diuretics | Hypertrophic or restrictive cardiomyopathy; correctable valvulopathy; acute coronary syndrome or coronary revascularization in past 3 mo.; scheduled revascularization; severe obstructive lung disease; indication for an ICD
Filho 2002^6^ | III or IV | < 30% | - | - | - | - | - | > 18 yr.; irreversible cause of cardiomyopathy; maximum medical therapy; clinically stable × 2 weeks; LBBB. | 2nd or 3rd degree heart block; acute myocarditis; unstable angina; referred for surgery
Gras 2002^7^ INSYNC Italian Registry | III or IV | <=35 | >150ms | >60mm | no | no | - | Refractory to medical therapy × 1 month | 18 yr.; had a contraindication to DDD pacing; unstable angina; acute MI < 3mo; permanent AF; presence of ICD; other life-limiting disease
Guidant^8^ CONTAK-CD FDA report 2002 | II, III or IV | <=35% | >=120 ms | - | yes | no | yes | Meet indications for ICD; diuretics and/or digoxin; >=18 yr. | Meet indications for antibradycardia pacing; refractory atrial tachycardia; require concomitant cardiac surgery; not suitable for the procedure
Krahn 2002^9^ | >=II | - | >=130 ms | - | yes | yes | - | HF stable × 1 mo. on best medical therapy unless intolerant, diuretics | HF caused by diastolic dysfunction; unable to provide f/u; life expectance <1 yr.
Kuhlkamp 2002^10^ | - | <=35 | >130 ms | >55 mm | no | no | - | Symptomatic sustained ventricular tachycardia and/or survival of cardiac arrest; symptomatic HF despite appropriate therapy | None stated
Leclercq 2002^11^ MUSTIC-AF | III | <35% | >200 ms | >60 mm | yes | no | no | Diuretics; AF >3 mo.; requiring pacing (AV ablation or spontaneously); 6MWT <450 m | Hypertrophic or restrictive cardiomyopathy; correctable valvulopathy; acute coronary syndrome or coronary revascularization in past 3 mo.; scheduled revascularization; severe obstructive lung disease; indication for an ICD
Leclercq 2000^12^ | III or IV | <=35 | >=120 ms | >=60 mm | yes | no | - | Drug refractory CHF; optimal medical therapy; diuretics | Suspected acute myocarditis; correctable valvular disease; acute coronary syndrome <3 mo.; CA revascularization within preceding 12 mo.
Leclercq^13^ unpublished | III or IV | <=35% | >120 ms (first 16 pts), then changed to 150 ms | >=60mm | - | - | - | - | Suspicion of acute myocarditis; patients who benefited from coronary revascularization procedure within the past 12 months; acute coronary “accident” in past 3 months; patients who could benefit from valvular surgery
Leclercq 2003* RD-CHF Unpublished | III or IV | <=35% | >180 ms | N/a | N/a | N/a | 48 | N/a | N/a
Leon 2002^14^ | III or IV | <=35 | - | - | - | - | - | Chronic AF; AV ablation and RV pacing >=6 mo.; symptoms refractory to standard medical care | None stated
Medtronic 2001^15^ MIRACLE-ICD FDA report | II, III or IV | <=35% | >=130 ms | >=55 mm | yes | no | no | ICD indication; =>18 yr.; previous MI; recurrent or sustained VT | Unstable angina; MI, CABG, PTCA, TIA or CVA in past 3 mo., indications for or contraindications against standard cardiac pacing; systolic BP <80 or >170mm; HR >140bpm; hepatic function >3 times upper limit of normal; primary valvular disease right heart valve; COPD; life expectancy <6 mo.
Molhoek 2002^6^ | III or IV | <=35 | >=120 ms or > 200 | - | - | - | - | LBBB | Not stated

ACEi = angiotensin converting enzyme inhibitors; AF = atrial fibrillation; BB =- beta blockers; BP= blood pressure; CABG = coronary artery bypass grafting; CHF = congestive heart failure; COPD = chronic obstructive lung disease; CVA = coronary vascular accident; FDA = Food and Drug Administration; f/u = followup; HD= heart disease; HR = heart rate; HX = history; ICD = implantable cardioverter-defibrillator; LBBB = left bundle branch block; LVEDD = left ventricular end diastolic diameter; LVEF = left ventricular ejection fraction; MI = myocardial infarction; N/a = not available; NYHA = New York Heart Association class; OPT = optimal pharmacological therapy; PTCA = percutaneous trans cardiac angioplasty; 6MWT = 6 min. walk test; TIA = transient ischemic attack; VT = ventricular tachycardia.

* detailed data not available for Leclercq 2003 (RD-CHF) at the time this report was prepared; information included in this report was obtained through personal communication with the author