# Appendix B: Sample Data Forms

## Sample Data Forms

Inclusion/Exclusion Criteria

- Form B-1 Inclusion Form: CRT for CHF: Efficacy Review
- Form B-2 Inclusion Form: CRT for CHF Safety Review

Quality Assessment

- Form B-3 Assessment of methodology for randomized controlled trials (RCT): Efficacy review
- Form B-4 Assessment of methodology for RCTs and non-RCTs: Safety Review

Data Extraction

- Form B-5 Data extraction - CRT for CHF: Efficacy review
- Form B-6 Data extraction - CRT for CHF: Safety review

Form B-1 Inclusion Form: CRT for CHF: Efficacy Review

Please assess each study according to the criteria below.

Form B-2 Inclusion Form: CRT for CHF Safety Review

Please assess each study according to the criteria below.

Form B-3 Assessment of methodology for randomized controlled trials (RCT)

Form B-4 Assessment of methodology for RCTs and non-RCTs: Safety Review

Form B-5 Data extraction - CRT for CHF: Efficacy review

Form B-6 Data extraction - CRT for CHF: Safety review