# Appendix A: Extract Search Strings

## Exact Search Strings

### Search Strategies

Basic Searches

- Table A-1 Medline - CRT for CHF
- Table A-2 EMBASE - CRT for CHF
- Table A-3 International Pharmaceutical Abstracts - CRT for CHF
- Table A-4 PubMed - CRT for CHF
- Table A-5 Web of Science - CRT for CHF

Safety Review Searches

- Table A-6 Medline - CRT for CHF
- Table A-7 EMBASE - CRT for CHF
- Table A-8 PubMed - CRT for CHF
- Tablel A-9 Web of Science - CRT for CHF

Efficacy Review Searches

- Table A-10 Medline - CRT for CHF; 1Oct02 (efficacy)
- Table A-11 EMBASE - CRT for CHF; 2Oct02 (efficacy)
- Table A-12 Cochrane Controlled Trials Register (CENTRAL) - CRT for CHF; 2Oct02 (efficacy)
- Table A-13 Database of Abstracts of Reviews of Effectiveness (DARE) - CRT for CHF; 2Oct02 (efficacy)
- Table A-14 Cochrane Database of Systematic Review - CRT for CHF; 2Oct02 (efficacy)
- Table A-15 PubMed - CRT for CHF (efficacy)
- Table A-16 Web of Science: CRT for CHF (efficacy)

## Search Strategies

### Electronic Databases

The search was designed by a medical librarian in consultation with a cardiologist (EC, JE), then performed systematically by the librarian (EC). The following electronic resources were searched:

- - The Cochrane Central Register of Controlled Trials (22)
- - DARE (2)
- - Cochrane Database of Systematic Reviews (2)
- - EMBASE (basic=4619, safety=1040, efficacy=1415)
- - International Pharmaceutical Abstracts (1)
- - MEDLINE (basic=9817, safety=2168, efficacy=444)
- - PubMed (basic=1558, safety=828, efficacy=449)
- - Web of Science (basic=313, safety=17, efficacy=27)

The total number of references with duplicates removed were 1697 (for the efficacy part of the review) and 1708 (safety).

### Trial Registries

Several trial registries were also searched using keywords from the searches below. These included:

- - http://www2.umdnj.edu/~shindler/trials/trials_a.html
- - http://www.nhlbi.nih.gov/index.htm
- - http://www.controlled-trials.com/
- - clinicaltrials.gov
- - http://www.update-software.com/National/
- - http://www.centerwatch.com/search.asp
- - http://www.cardiosource.com

Each trial retrieved from the registries was reviewed independently by two investigators.

### Companies

The companies that manufacture biventricular devices were contacted:

- - Medtronic
- - Guidant
- - ELA Medical (Montrouge, France)

### Keywords and Subject Headings

The search strategies included the following keywords and appropriate subject headings, specifically tailored for each resource: Biventricular pacing, biventricular pacer, biventricular stimulation, Biv, congestive heart failure, Chf, chronic heart failure, artificial cardiac pacing, heart diseases, chronic cardiac failure resynchronization therapy, dual-chamber pacing, cardiac resynchronization, Medtronic, Insync, ELA medical; randomized controlled trial, controlled clinical trial, meta-analysis, multi-center trial; safety, risk, adverse effects, side effects, harm, etiology, aetiology, contraindications, causation, causality, predict.

The search process also involved: citation searches; contacting the primary author of key, ongoing or unpublished studies, and reviewing the reference lists of all selected articles.

The search was not limited by language or publication status.

The detailed search strings appear on the following pages. They cover the years 1988 to the present (June 2003).

## Basic Searches

Table A-1 Medline -CRT for CHF: (basic search)

Set | Search
1 | (biventricular adj (pacing or pacer$ or stimulat$)).mp.
2 | resynchronization therapy.mp.
3 | biv.mp.
4 | (dual-chamber adj (pacing or pacer$ or stimulat$)).mp.
5 | ((cardiac or heart) adj resynchronization).mp.
6 | medtronic.mp.
7 | Insync.mp.
8 | “ela medical”.mp.
9 | exp cardiac pacing, artificial/
10 | or/1–8
11 | or/1–9
12 | exp heart failure, congestive/
13 | “congestive heart failure$”.mp.
14 | chf.mp.
15 | exp heart diseases/
16 | “congestive cardiac failure$”.mp.
17 | “chronic cardiac failure$”.mp.
18 | “chronic heart failure$”.mp.
19 | or/12–18
20 | 10 and 19
21 | 11 and 19

CRT= cardiac resynchronization therapy; CHF= congestive heart failure

Table A-2 EMBASE: CRT for CHF - (basic search)

Set | Search
1 | (biventricular adj (pacing or pacer$ or stimulat$)).mp.
2 | exp heart pacing/
3 | resynchronization therapy.mp.
4 | biv.mp.
5 | (dual-chamber adj (pacing or pacer$ or stimulat$)).mp.
6 | ((cardiac or heart) adj resynchronization).mp.
7 | medtronic.mp.
8 | insync.mp.
9 | “ela medical”.mp.
10 | or/1–9
11 | exp Congestive heart failure/
12 | “congestive heart failure$”.mp.
13 | chf.mp.
14 | exp Heart disease/
15 | “congestive cardiac failure$”.mp.
16 | “chronic cardiac failure$”.mp.
17 | “chronic heart failure$”.mp.
18 | or/11–17
19 | 10 and 18

CRT= cardiac resynchronization therapy; CHF= congestive heart failure

Table A-3 nternational Pharmaceutical Abstracts CRT for CHF (basic search)

Set | Search
1 | (biventricular adj (pacing or pacer$ or stimulat$)).mp.
2 | resynchronization therapy.mp.
3 | biv.mp.
4 | (dual-chamber adj (pacing or pacer$ or stimulat$)).mp.
5 | ((cardiac or heart) adj resynchronization).mp.
6 | “cardiac pacing”.mp.
7 | medtronic.mp.
8 | insync.mp.
9 | “ela medical”.mp.
10 | or/1–9
11 | “congestive cardiac failure$”.mp.
12 | “congestive heart failure$”.mp.
13 | chf.mp.
14 | heart disease$.mp.
15 | “chronic cardiac failure$”.mp.
16 | “chronic heart failure$”.mp.
17 | or/11–16
18 | 10 and 17

CRT= cardiac resynchronization therapy; CHF= congestive heart failure

Table A-4 PubMed: CRT for CHF (basic search)

#19 | Search #10 AND # 18
#18 | Search #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17
#17 | Search “CHRONIC HEART FAILURE*”
#16 | Search “CHRONIC CARDIAC FAILURE*”
#15 | Search “CONGESTIVE CARDIAC FAILURE*”
#14 | Search HEART DISEASES[MESH]
#13 | Search CHF
#12 | Search “CONGESTIVE HEART FAILURE”
#11 | Search HEART FAILURE, CONGESTIVE[MESH]
#10 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8
#8 | Search “ELA MEDICAL”
#7 | Search INSYNC
#6 | Search MEDTRONIC
#5 | Search (CARDIAC OR HEART) AND RESYNCHRONIZATION
#4 | Search DUAL-CHAMBER AND (PACING OR PACER* OR STIMULAT*)
#3 | Search BIV
#2 | Search RESYNCHRONIZATION THERAPY
#1 | Search biventricular AND (PACING OR PACER* OR STIMULAT*)

CRT= cardiac resynchronization therapy; CHF= congestive heart failure

Table A-5 Web of Science: CRT for CHF (basic search)

#3 | 316 | #1 AND #2
#2 | 84,712 | TS=(congestive heart failure* or chf or heart disease or congestive cardiac failure* or chronic cardiac failure* or chronic heart failure*)
#1 | 3,268 | TS=(biventricular pacing OR biventricular pacer* OR resynchronization therapy OR biv OR dual chamber pacing OR dual chamber pacer* OR dual chamber stimulat* OR cardiac resynchronization OR heart resynchronization OR cardiac pacing OR medtronic OR insync OR ela medical)

CRT= cardiac resynchronization therapy; CHF= congestive heart failure

## Safety Searches

Table A-6 Medline: CRT for CHF - (safety search)

Set | Search
1 | (biventricular adj (pacing or pacer$ or stimulat$)).mp.
2 | resynchronization therapy.mp.
3 | biv.mp.
4 | (dual-chamber adj (pacing or pacer$ or stimulat$)).mp.
5 | ((cardiac or heart) adj resynchronization).mp.
6 | medtronic.mp.
7 | insync.mp.
8 | “ela medical”.mp.
9 | exp cardiac pacing, artificial/
10 | or/1–8
11 | or/1–9
12 | exp heart failure, congestive/
13 | exp heart diseases/
14 | “congestive cardiac failure$”.mp.
15 | “congestive heart failure$”.mp.
16 | “chronic cardiac failure$”.mp.
17 | “chronic heart failure$”.mp.
18 | chf.mp.
19 | or/12–18
20 | 10 and 19
21 | 11 and 19
22 | (safe or safety).mp.
23 | risk$.mp.
24 | exp risk/
25 | adverse effect$.mp.
26 | side effect$.mp.
27 | harm.mp.
28 | etiology.mp.
29 | aetiology.mp.
30 | contraindicat$.mp.
31 | (cause or causation or causing or causal$).mp.
32 | exp causality/
33 | predict$.mp.
34 | or/22–33
35 | 20 and 34
36 | 21 and 34

CRT= cardiac resynchronization therapy; CHF= congestive heart failure

Table A-7 EMBASE: CRT for CHF- (safety search)

Set | Search
1 | (biventricular adj (pacing or pacer$ or stimulat$)).mp.
2 | exp heart pacing/
3 | resynchronization therapy.mp.
4 | biv.mp.
5 | (dual-chamber adj (pacing or pacer$ or stimulat$)).mp.
6 | ((cardiac or heart) adj resynchronization).mp.
7 | medtronic.mp.
8 | insync.mp.
9 | “ela medical”.mp.
10 | or/1–9
11 | exp Congestive heart failure/
12 | “congestive heart failure$”.mp.
13 | chf.mp.
14 | exp Heart disease/
15 | “congestive cardiac failure$”.mp.
16 | “chronic cardiac failure$”.mp.
17 | “chronic heart failure$”.mp.
18 | or/11–17
19 | 10 and 18
20 | (safe or safety).mp.
21 | exp risk/
22 | risk$.mp.
23 | exp Side effect/
24 | “side effect$”.mp.
25 | “HARM”.mp.
26 | exp etiology/
27 | aetiology.mp.
28 | Treatment contraindication/
29 | contraindicat$.mp.
30 | (cause or causation or causing or causal$).mp.
31 | *Epidemiology/
32 | exp prediction/
33 | or/20–32
34 | 19 and 33

CRT= cardiac resynchronization therapy; CHF= congestive heart failure

Table A-8 PubMed: CRT for CHF (safety search)

#30 | Search #18 OR #19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29
#29 | Search predict*
#28 | Search CAUSALITY[MESH]
#27 | Search cause OR CAUSATION OR CAUSING OR CAUSAL*
#26 | Search contraindicat*
#25 | Search aetiology
#24 | Search etiology
#23 | Search HARM
#22 | Search side effect*
#21 | Search adverse effect*
#20 | Search RISK[MESH]
#19 | Search RISK*
#18 | Search SAFE OR SAFETY
#17 | Search #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16
#16 | Search CHF
#15 | Search “CHRONIC HEART FAILURE*”
#14 | Search “CHRONIC CARDIAC FAILURE*”
#13 | Search “CONGESTIVE HEART FAILURE*”
#12 | Search “CONGESTIVE CARDIAC FAILURE*”
#11 | Search HEART DISEASES[MESH]
#10 | Search HEART FAILURE, CONGESTIVE[MESH]
#9 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8
#8 | Search ELA MEDICAL
#6 | Search MEDTRONIC
#7 | Search INSYNC
#5 | Search (CARDIAC OR HEART) AND RESYNCHRONIZATION
#4 | Search DUAL-CHAMBER AND (PACING OR PACER* OR STIMULAT*)
#1 | Search biventricular AND (PACING OR PACER* OR STIMULAT*)
#3 | Search BIV
#2 | Search RESYNCHRONIZATION THERAPY

CRT= cardiac resynchronization therapy; CHF= congestive heart failure

Table A-9 Web of Science: CRT for CHF (safety search)

#4 | #1 AND #2 AND #3
#3 | TS=(safe or safety or risk* or adverse effect* or side effect* or harm or etiology or aetiology or contraindicat* or cause or causation or causing or causal* or predict*)
#2 | TS=(congestive heart failure* or chf or heart disease or congestive cardiac failure* or chronic cardiac failure* or chronic heart failure*)
#1 | TS=(biventricular pacing or biventricular pacer* or resynchronization therapy or biv or dual-chamber pacing or dual-chamber pacer* or dual-chamber stimulat* or cardiac resynchronization or heart resynchronization or cardiac pacing or medtronic or insync or ela medical)

CRT= cardiac resynchronization therapy; CHF= congestive heart failure

## Efficacy Searches

Table A-10 Medline: CRT for CHF (efficacy search)

Set | Search
1 | (biventricular adj (pacing or pacer$ or stimulat$)).mp.
2 | resynchronization therapy.mp.
3 | biv.mp.
4 | (dual-chamber adj (pacing or pacer$ or stimulat$)).mp.
5 | ((cardiac or heart) adj resynchronization).mp.
6 | medtronic.mp.
7 | insync.mp.
8 | “ela medical”.mp.
9 | exp cardiac pacing, artificial/
10 | or/1–8
11 | or/1–9
12 | exp heart failure, congestive/
13 | “congestive heart failure$”.mp.
14 | chf.mp.
15 | exp heart diseases/
16 | “congestive cardiac failure$”.mp.
17 | “chronic cardiac failure$”.mp.
18 | “chronic heart failure$”.mp.
19 | or/12–18
20 | 10 and 19
21 | 11 and 19
22 | limit 20 to (controlled clinical trial or meta analysis or multicenter study or randomized controlled trial)
23 | limit 21 to (controlled clinical trial or meta analysis or multicenter study or randomized controlled trial)

CRT= cardiac resynchronization therapy; CHF= congestive heart failure

Table A-11 EMBASE: CRT for CHF -(efficacy search)

Set | Search
1 | (biventricular adj (pacing or pacer$ or stimulat$)).mp.
2 | exp heart pacing/
3 | resynchronization therapy.mp.
4 | biv.mp.
5 | (dual-chamber adj (pacing or pacer$ or stimulat$)).mp.
6 | ((cardiac or heart) adj resynchronization).mp.
7 | medtronic.mp.
8 | insync.mp.
9 | “ela medical”.mp.
10 | or/1–9
11 | exp Congestive heart failure/
12 | “congestive heart failure$”.mp.
13 | chf.mp.
14 | exp Heart disease/
15 | “congestive cardiac failure$”.mp.
16 | “chronic cardiac failure$”.mp.
17 | “chronic heart failure$”.mp.
18 | or/11–17
19 | 10 and 18
20 | “randomized controlled trial”/
21 | random$.mp.
22 | exp controlled study/
23 | “meta analysis”/
24 | multi center trial$.mp.
25 | “systematic review$”.mp.
26 | or/20–25
27 | 19 and 26

CRT= cardiac resynchronization therapy; CHF= congestive heart failure

Table A-12 Cochrane Controlled Trials Register (CENTRAL): CRT for CHF -(efficacy search)

Set | Search
1 | (biventricular adj (pacing or pacer$ or stimulat$)).mp.
2 | resynchronization therapy.mp.
3 | biv.mp.
4 | (dual-chamber adj (pacing or pacer$ or stimulat$)).mp.
5 | ((cardiac or heart) adj resynchronization).mp.
6 | medtronic.mp.
7 | insync.mp.
8 | “ela medical”.mp.
9 | or/1–8
10 | “congestive heart failure$”.mp.
11 | chf.mp.
12 | heart disease$.mp.
13 | “congestive cardiac failure$”.mp.
14 | “chronic cardiac failure$”.mp.
15 | “chronic heart failure$”.mp.
16 | or/10–15
17 | 9 and 16

CRT=cardiac resynchronization therapy; CHF=congestive heart failure

Table A-13 Database of Abstracts of Reviews of Effectiveness (DARE): CRT for CHF - (efficacy search)

Set | Search
1 | (biventricular adj (pacing or pacer$ or stimulat$)).mp.
2 | resynchronization therapy.mp.
3 | biv.mp.
4 | (dual-chamber adj (pacing or pacer$ or stimulat$)).mp.
5 | ((cardiac or heart) adj resynchronization).mp.
6 | medtronic.mp.
7 | insync.mp.
8 | “ela medical”.mp.
9 | or/1–8
10 | “congestive heart failure$”.mp.
11 | chf.mp.
12 | heart disease$.mp.
13 | “congestive cardiac failure$”.mp.
14 | “chronic cardiac failure$”.mp.
15 | “chronic heart failure$”.mp.
16 | or/10–15
17 | 9 and 16

CRT= cardiac resynchronization therapy; CHF= congestive heart failure

Table A-14 Cochrane Database of Systematic Reviews: CRT for CHF - (efficacy search)

Set | Search
1 | (biventricular adj (pacing or pacer$ or stimulat$)).mp.
2 | resynchronization therapy.mp.
3 | biv.mp.
4 | (dual-chamber adj (pacing or pacer$ or stimulat$)).mp.
5 | ((cardiac or heart) adj resynchronization).mp.
6 | medtronic.mp.
7 | insync.mp.
8 | “ela medical”.mp.
9 | or/1–8
10 | “congestive heart failure$”.mp.
11 | chf.mp.
12 | heart disease$.mp.
13 | “congestive cardiac failure$”.mp.
14 | “chronic cardiac failure$”.mp.
15 | “chronic heart failure$”.mp.
16 | or/10–15
17 | 9 and 16

CRT= cardiac resynchronization therapy; CHF= congestive heart failure

Table A-15 PubMed: CRT for CHF (efficacy search)

#25 | Search #19 AND #24
#23 | Search MULTICENTER STUDY
#24 | Search #20 OR #21 OR #22 OR #23
#22 | Search meta analysis
#21 | Search controlled clinical trial*
#20 | Search RANDOMIZED CONTROLLED TRIAL[PT]
#19 | Search #10 AND #18
#18 | Search #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17
#17 | Search “CHRONIC HEART FAILURE*”
#16 | Search “CHRONIC CARDIAC FAILURE*”
#15 | Search “CONGESTIVE CARDIAC FAILURE*”
#14 | Search HEART DISEASES[MESH]
#13 | Search CHF
#12 | Search “CONGESTIVE HEART FAILURE*”
#11 | Search HEART FAILURE, CONGESTIVE[MESH]
#10 | Search #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8
#8 | Search ELA MEDICAL
#7 | Search INSYNC
#6 | Search MEDTRONIC
#5 | Search (CARDIAC OR HEART) AND RESYNCHRONIZATION
#4 | Search DUAL-CHAMBER AND (PACING OR PACER* OR STIMULAT*)
#3 | Search BIV
#2 | Search RESYNCHRONIZATION THERAPY
#1 | Search biventricular AND (PACING OR PACER* OR STIMULAT*)

CRT= cardiac resynchronization therapy; CHF= congestive heart failure

Table A-16 Web of Science: CRT for CHF (efficacy search)

#4 | 31 | #1 AND #2 AND #3
#3 | >100,000 | TS=(random* or controlled trial* or clinical trial* or multi-center or meta-analys* or systematic review*)
#2 | 84,712 | TS=(congestive heart failure* or chf or heart disease or congestive cardiac failure* or chronic cardiac failure* or chronic heart failure*)
#1 | 3,268 | TS=(biventricular pacing or biventricular pacer* or resynchronization therapy or biv or dual-chamber pacing or dual-chamber pacer* or dual-chamber stimulat* or cardiac resynchronization or heart resynchronization or cardiac pacing or medtronic or insync or ela medical)

CRT= cardiac resynchronization therapy; CHF= congestive heart failure