# Listing of Studies Excluded at Level 2

[Breast cancer diagnostics. Finnish Breast Cancer Group]. [Finnish]. Duodecim 1999;115(13):1426–31.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
[Early diagnosis--guidelines and preparation. Meeting of Experts, Berlin, 8–9 September 1999]. Meeting of Experts, Berlin, 8–9 September 1999]. [German]. Radiologe 1999;39(10):M163–4.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
[Management of estrogen deficiency in women after breast cancer therapy]. [Review][30 refs][Polish]. Pol Arch Med Wewn 2001;105(5):355–9.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
[Quality control in anatomo-cytopathology. Breast cancer]. [Review][24 refs][French]. Arch Anat Cytol Pathol 1995;43(1–2):101–5.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Advanced breast carcinoma in the postmenopause - Is anastrozole a potential new gold standard?. Dtsch Apoth Ztg 1999;139(40):48–50.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Best at 100 top. Breast cancer management. Mod Healthc. 2001;26:Suppl:32–3.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Breast cancer consensus report. Med J Aust. 1994;161 Suppl:S1–16.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Breast cancer diagnosis. Screening and evaluation. Institute for Clinical Systems Improvement. Postgrad Med 2000; 108(5):191–2.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Breast cancer--new health outcomes and accountability. Manag Care Interface. 1998;11(1):38
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Cancer: a special case. Nurs Times. 1994;90(21):3–31.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Certified case manager news. Mammography recommendations updated: HHS affirms value of mammography for detecting breast cancer. Care Management 2002:8(3):44.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Consensus conference 2000: adjuvant therapy for breast cancer. National Institutes of Health Consensus Development Conference Statement November 1–3, 2000. Cancer Control 2000;8(1):55.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Consensus Conference on ‘Follow-up of Breast Cancer Patients’. Ann Oncol. 1995;6 (Suppl 2):69–70.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Delayed diagnosis of breast cancer. Int J Qual Health Care. 1998;10(6):561.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Employer group wants expanded measures. Disease State Management. 1996;2(7):78–9.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Every defect is a treasure. Int J Qual Health Care. 1996;8(3):297–8.
Not breast cancer in women.
Executive summary of the health care productivity report. J Ambul Care Manage. 2001;24(2):1–10.
Not breast cancer in women.
From the Centers for Disease Control and Prevention. Strategies for providing follow-up and treatment services in the National Breast and Cervical Cancer Early Detection Program--United States, 1997. JAMA 1998;279(24):1941–2.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Full-field digital mammography. TEC Bull (Online). 2002;19(1):1–4.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Guidelines for surgeons in the management of symptomatic breast disease in the United Kingdom. Eur J Surg Oncol. 1995;21 Suppl A:1–13.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
High-quality mammography: information for referring providers. J Am Acad Nurse Pract. 1995;7(2):73–82.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hospitals unite to improve breast cancer treatment. Rep Med Guidel Outcomes Res. 2000;11(13):10–2.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Mammography: what's a woman to do?. Johns Hopkins Med Lett Health After 50 2002;14(4):4–5.
Not breast cancer diagnosis or treatment.
NCCN practice guidelines. Screening for and evaluation of suspicious breast lesions. National Comprehensive Cancer Network. Acta Radiol Oncol 1998;12(11A):89–138.
Not breast cancer diagnosis or treatment.
New “patient-friendly” version of clinical breast cancer guidelines. CA Cancer J Clin. 1999;49(2):68.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
NIH consensus panel recommends a range of adjuvant therapies for women with breast cancer. J Am Coll Surg. 2001;192(2):288.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
NIH recommends range of adjuvant breast cancer therapies. Cancer Pract. 2001;9(2):57.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Oncology Section of the American Physical Therapy Association position statement -- Physical therapy: management of lymphedema in patients with a history of cancer. Rehabil Oncol. 2000;18(1):9–12.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Quality standards and certification requirements for mammography facilities--FDA. Interim rule with request for comments. Fed Regist 1993;58(243):67565–72.
Not breast cancer in women.
Recommendations for the reporting of breast carcinoma. Association of Directors of Anatomic and Surgical Pathology. Am J Clin Pathol 1995;104(6):614–9.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Recommendations for the reporting of breast carcinoma. Association of Directors of Anatomic and Surgical Pathology. Mod Pathol 1996;9(1):77–81.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Recommendations of the Association of Directors of Anatomic and Surgical Pathology. Part I. Immediate management of mammographically detected breast lesions. Hum Pathol 1993;24(7):689–90.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Regional differences are part of breast cancer care. Healthc Benchmarks. 2001;8(8):91–3.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Requirements for accrediting bodies of mammography facilities--FDA. Interim rule with request for comments. Fed Regist 1993;58(243):67558–65.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Researchers test system to custom-tailor guidelines. Clin Resour Manag. 2001;3(1):8–10.
Not breast cancer in women.
Standardization of breast radiotherapy (START) trial. START Trial Management Group. Clin Oncol (R Coll Radiol) 1999;11(3):145–7.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Statement of the American Society of Human Genetics on genetic testing for breast and ovarian cancer predisposition. Am J Hum Genet. 1994;55(5):i–iv.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Summaries for patients. Chemotherapy in women with breast cancer.[original report in Ann Intern Med. 2003 Jan 21;138(2):90–7; PMID: 12529090]. Ann Intern Med. 2003;138(2):I16.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Teamworks. Reducing turnaround time (TAT) for breast cancer diagnosis. Joint Commission Benchmark. 2002;4(2):8-9.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Consensus Conference on Paclitaxel. The Fox Chase Cancer Center, Free University Hospital Investigators' Workshop. Part 1: Breast Cancer I. Semin Oncol. 1996;23(5 Suppl 11):1-70. [pmid: 8966623].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Consensus Conference on Paclitaxel. The Fox Chase Cancer Center, Free University Hospital Investigators' Workshop. Part 4: Breast Cancer II. Marrakech, Morocco, January 18–20, 1996 and St Croix, US Virgin Islands, March 13–16, 1996. Semin Oncol. 1996;24(1 Suppl 3):1-49.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
The requirements of a specialist breast unit.[comment]. Eur J Cancer 2000;36(18):2288–93.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. CMAJ. 1998;10:158 Suppl 3:S1–2.
Not breast cancer diagnosis or treatment.
Treatment of estrogen deficiency symptoms in women surviving breast cancer. The Hormone Foundation, Canadian Breast Cancer Research Initiative, National Cancer Institute of Canada, Endocrine Society, and the University of Virginia Cancer Center and Woman's Place. [Review][44 refs]. J Clin Endocrinol Metab 1998;83(6):1993–2000.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Treatment of estrogen deficiency symptoms in women surviving breast cancer. [Review][44 refs]. Climacteric 1998;1(2):148–58.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Tumour markers in breast cancer--EGTM recommendations. European Group on Tumor Markers. [Review][41 refs]. Anticancer Res 1999;19(4A):2803–5.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Unprecedented survival with Xeloda (capecitabine) combination in metastatic breast cancer: XELODA combination extends breast cancer survival and sets a new standard of care. Scottish Nurse. 2002;7(1):43
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Abrams J, Chen T, Giusti R. Special communication from the National Cancer Institute. Survival after breast-sparing surgery versus mastectomy. J Natl Cancer Inst. 1994;86(22):1672-3. [pmid: 7966392].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Adderley U. Topical agents and dressings for fungating wounds. Cochrane Database Syst Rev. 2003;1, 2003.
Not breast cancer in women.
Ader M. Investigational treatments: coverage, controversy, and consensus. Ann Health Law 1996;(5):45–60.
Not breast cancer in women.
Aikin J L. Clinical trials corner. Setting a new standard of care in adjuvant breast cancer chemotherapy. Innovations in Breast Cancer Care. 2000;5(2):35-6.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Akid M. Breast cancer. Are we failing the screen test?. Nurs Times. 2002;98(18):14. [pmid: 12219451].
May Not breast cancer diagnosis or treatment.
Alder S. Guidelines for the surgical management of breast cancer: comment. Aust N Z J Surg. 1999;69(10):748. [pmid: 10527357].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Alderman A K, McMahon L, Wilkins E G. The national utilization of immediate and early delayed breast reconstruction and the effect of sociodemographic factors. Keisei Geka. 2003;111(2):695-703.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Alferi S M, Carver C S, Antoni M H, et al. An exploratory study of social support, distress, and life disruption among low-income Hispanic women under treatment for early stage breast cancer. Health Psychol. 2001;20(1):41-6. [pmid: 11199065].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Allgar V L, Neal R D, Pascoe S W. Grading referrals to specialist breast units. Guidance on referral needs to be evidence based. BMJ. 2002;325(7360):392. [pmid: 12183322].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Alliot F, Launois R. [Lymphedema and quality of life]. [Review] [11 refs] [French]. Rev Med Interne. 2002;23(Suppl 3):431s-435s. [pmid: 12162209].
Not breast cancer in women.
American College, of Obstetricians, Gynecologists. ACOG Practice Bulletin: Clinical Management Guidelines for Obstetrician-Gynecologists: Number 39, October 2002. Selective estrogen receptor modulators. Curr Opin Obstet Gynecol. 2002;100(4):835-43.
Not breast cancer in women.
Andersen H, Haustermans K, Glindtvad K. A clinical quality management support system. Stud Health Technol Inform. 1997;43 Pt B849–53.
Not breast cancer in women.
Anderson E A, Zwelling L A. Measuring service quality at the University of Texas M.D. Anderson Cancer Center. Int J Health Care Qual Assur. 1996;9(7):9-22. [pmid: 10162922].
Not breast cancer diagnosis or treatment.
Antman K H. Overview of the six available randomized trials of high-dose chemotherapy with blood or marrow transplant in breast cancer. J Natl Cancer Inst Monogr. 2001;30:114-6. [pmid: 11773303].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Antman K H. A critique of the eleven randomised trials of high-dose chemotherapy for breast cancer. Eur J Cancer. 2001;37(2):173-9. [pmid: 11166143].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Arcarese J S. Why MQSA? Why now?. Radiol Technol. 1994;66(1):53-6. [pmid: 7997527].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Austin C. First person. Good of small things. Health Serv J. 2003;113(5842):29. [pmid: 12622028].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Badger C. Physical therapies for reducing and controlling lymphoedema of the limbs. Cochrane Database Syst Rev. 2003;1, 2003.
Not breast cancer in women.
Badwe R A, Mittra I, Havaldar R. Timing of surgery during the menstrual cycle and prognosis of breast cancer. J Biosci. 2000;25(1):113-20. [pmid: 10824205].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bailar J C. Surgery for early breast cancer--can less be more?. N Engl J Med. 1995;333(22):1496-8. [pmid: 7477152].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Baker J A, Soo M S. Breast US: assessment of technical quality and image interpretation. Radiology. 2002;223(1):229-38. [pmid: 11997557].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ballard-Barbash R, Potosky A L, Harlan L C, et al. Factors associated with surgical and radiation therapy for early stage breast cancer in older women. J Natl Cancer Inst. 1996;88(11):716-26. [pmid: 8637025].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Barnett G R. “Best practice” in surgical management of breast cancer.[comment]. Med J Aust. 1997;167(10):557-8. [pmid: 9397050].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bartelink H, Horiot J C, Poortmans P, et al. Recurrence rates after treatment of breast cancer with standard radiotherapy with or without additional radiation.[comment]. N Engl J Med. 2001;345(19):1378-87. [pmid: 11794170].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bartlett E E, Holman K I. Reducing malpractice risk and increasing quality in managed care. Manag Care Interface. 1998;11(5):68-72. [pmid: 10181555].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bassett L, Winchester D P, Caplan R B, et al. Stereotactic core-needle biopsy of the breast: a report of the Joint Task Force of the American College of Radiology, American College of Surgeons, and College of American Pathologists. Breast J. 1997;3(6):317-30.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bates T, Evans R G. Audit of brachial plexus neuropathy following radiotherapy. Clin Oncol (R Coll Radiol). 1995;7(4):236. [pmid: 8845319].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Baum M, Ravdin P M. Decision-making in early breast cancer: guidelines and decision tools. Eur J Cancer. 2002;38(6):745-9. [pmid: 11937306].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Beckmann M W, Schnurch H G, Bodden-Heidrich R, et al. Early cancer detection programmes for women at high risk for breast and ovarian cancer: a proposal of practical guidelines. [Review] [87 refs]. Eur J Cancer Prev. 1996;5(6):468-75. [pmid: 9061278].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Begg C B. The mammography controversy.[comment]. [Review] [16 refs]. Oncologist. 2002;7(3):174-6. [pmid: 12065786].
Not breast cancer diagnosis or treatment.
Beitler A L, Hurd T C, Edge S B. The evaluation of palpable breast masses: common pitfalls and management guidelines. Surg Oncol. 1997;6(4):227-34. [pmid: 9775409].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bell C M, Ma M, Campbell S, et al. Methodological issues in the use of guidelines and audit to improve clinical effectiveness in breast cancer in one United Kingdom health region. Eur J Surg Oncol. 2000;26(2):130-6. [pmid: 10744929].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bellocq J-P. Quality assurance in breast diseases. Ann Pathol. 1997;17(5 Suppl.):70-1. [pmid: 9453729].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Benz C, Clark G, Conzen S, et al. Consensus statement: Expedition Inspiration fund for breast cancer research meeting 2002. Breast Cancer Res Treat. 2003;78(1):127-31. [pmid: 12611465].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Berg W A, D'Orsi C J, Jackson V P, et al. Does training in the Breast Imaging Reporting and Data System (BI-RADS) improve biopsy recommendations or feature analysis agreement with experienced breast imagers at mammography?. Radiology. 2002;224(3):871-80. [pmid: 12202727].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bernhard J, Sullivan M, Hurny C, et al. Clinical relevance of single item quality of life indicators in cancer clinical trials. Br J Cancer. 2001;84(9):1156-65. [pmid: 11336464].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bertino J R, O'Connor O A. Do we need a new strategy to treat metastatic breast cancer?. Curr Oncol Rep. 1999;1(2):85-7. [pmid: 11122803].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bickell N A, Chassin M R. Determining the quality of breast cancer care: do tumor registries measure up?[comment]. Ann Intern Med. 2000;132(9):705-10. [pmid: 10787363].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bickell N A, Aufses A H, Chassin M. Engaging clinicians in a quality improvement strategy for early-stage breast cancer treatment. Qual Manag Health Care. 1998;6(3):63-8. [pmid: 10182541].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bijker N, Rutgers E J, Peterse J L, et al. Variations in diagnostic and therapeutic procedures in a multicentre, randomized clinical trial (EORTC 10853) investigating breast-conserving treatment for DCIS. Eur J Surg Oncol. 2001;27(2):135-40. [pmid: 11289747].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bilous M, Dowsett M, Hanna W, et al. Current perspectives on HER2 testing: A review of National Testing Guidelines. Mod Pathol. 2003;16(2):173-82. [pmid: 12591971].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bland K I. Failure of routine axillary nodal sampling to predict survival outcomes in lymph node-negative (N0) breast cancer.[comment]. Ann Surg. 2003;237(2):168-70. [pmid: 12724640]. [pmcid: 1522137].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bland K I, Menck H R, Scott-Conner C E, et al. The National Cancer Data Base 10-year survey of breast carcinoma treatment at hospitals in the United States. Cancer. 1998;83(6):1262-73. [pmid: 9874473].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Boccardo F, Blamey RW, Klijn JG, et al. LHRH-Agonist (LHRH-A) + Tamoxifen (TAM) Versus LHRH-A Alone in Premenopausal Women with Advanced Breast Cancer (ABC): Results of a Meta-Analysis of Four Trials (Meeting abstract).
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Boehm T, Garzoli E, Marincek B. [Differential diagnosis of benign and malignant mammary lesions with special regard to the BI-RADS((R)) classification system in mammography]. [German]. Gynakol Geburtshilfliche Rundsch. 2002;42(4):191-200. [pmid: 12373023].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Boerner S, Fornage B D, Singletary E, et al. Ultrasound-guided fine-needle aspiration (FNA) of nonpalpable breast lesions: a review of 1885 FNA cases using the National Cancer Institute-supported recommendations on the uniform approach to breast FNA.[comment]. Cancer. 1999;87(1):19-24. [pmid: 10096355].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bontenbal M, Nortier J W, Beex L V, et al. [Adjuvant systemic therapy for patients with resectable breast cancer: guideline from the Dutch National Breast Cancer Platform and the Dutch Society for Medical Oncology]. [Dutch]. Ned Tijdschr Geneeskd. 2000;144(21):984-9. [pmid: 10858788].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Booth-Clibborn N, Milne R, Oliver S. Searching for high-quality evidence to prepare patient information. Health Info Libr J. 2001;18(2):75-82. [pmid: 11780736].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bouaud J, Seroussi B, Antoine EC, et al. Hypertextual navigation operationalizing generic clinical practice guidelines for patient-specific therapeutic decisions. Proc AMIA Symp 1998, Annual Symposium.488–92.
Not breast cancer diagnosis or treatment.
Bourez R L, Rutgers E J, Van De Velde C J, et al. Will we need lymph node dissection at all in the future?. [Review] [148 refs]. Clin Breast Cancer. 2002;3(5):315-22. [pmid: 12533260].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Brandt R T, Lynch H T. BRCA1 and BRCA2: to test or not to test. Breast Cancer Res Treat. 2001;67(2):187-8. [pmid: 11519868].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Branston L, Greening S. Are computerised pathology reporting guidelines an effective technology for improving the quality of cancer reporting and registration? [abstract]. Annu Meet Int Soc Technol Assess Health Care. 2002;13159.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Branston L K, Greening S, Newcombe R G, et al. The implementation of guidelines and computerised forms improves the completeness of cancer pathology reporting. The CROPS project: a randomised controlled trial in pathology. Eur J Cancer. 2002;38(6):764-72. [pmid: 11937309].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bressoud D, Casabianca A, De Wolf C, et al. Guidelines to improve communication/information on breast cancer. Med Hyg (Geneve). 2003;Date of Publication26
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Broadstock M, Michie S, Marteau T. Psychological consequences of predictive genetic testing: a systematic review. [Review] [73 refs]. Eur J Hum Genet. 2000;8(10):731-8. [pmid: 11039571].
Not breast cancer diagnosis or treatment.
Browman G P, Levine M N, Mohide E A, et al. The practice guidelines development cycle: a conceptual tool for practice guidelines development and implementation. J Clin Oncol. 1995;13(2):502-12. [pmid: 7844612].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Brown M L, Hankey B F, Ballard-Barbash R. Measuring the quality of breast cancer care. Ann Intern Med. 2000;133(11):920. [pmid: 11103066].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Brown S C. More on breast cancer guidelines.[comment]. CMAJ. 1998;158(11):1425-30. [pmid: 9629095].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Buick DL., Petrie KJ, Booth R, et al. Emotional and functional impact of radiotherapy and chemotherapy on patients with primary breast cancer.. 2000;1839–62.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bultz B D, Speca M. Comment on: The EUSOMA Position Paper on the requirements of a specialist breast unit, Eur J Cancer. 2000;36:2288–93. Eur J Cancer. 2001;37(12):1579-80. [pmid: 11510500].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Bunnell C A, Winer E P. Lumping versus splitting: the splitters take this round. J Clin Oncol. 2002;20(17):3576-7. [pmid: 12202656].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Busch E, Kemeny M, Fremgen A, et al. Patterns of breast cancer care in the elderly. Cancer. 1996;78(1):101-11. [pmid: 8646705].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Buysse DJ. Pittsburgh Sleep Quality Index. Andrykowski, M.A, Curran SL, Lightner R. Off-treatment fatigue in breast cancer survivors: A controlled comparison. J Behav Med 1998;21:1–18.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Buzdar A U, Come S E, Brodie A, et al. Proceedings of the First International Conference on Recent Advances and Future Directions in Endocrine Therapy for Breast Cancer: summary consensus statement. Clin Cancer Res. 2001;7(12 Suppl):4335s-7s. [pmid: 11916221].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Cammilluzzi E. [6th International Conference. Adjuvant therapy of breast cancer in the first stages. 26–28 February 1998, St. Gallen, Switzerland]. [Italian]. Clin Ter 1998;149(2):99–103.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Candeira M, Schuch W, Greiner L, et al. American Cancer Society Lymphedema Workshop: Workgroup V: Collaboration and advocacy. Cancer. 1998;83(12 Suppl American):2888-90. [pmid: 9874419].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Capron A M. Practice guidelines: how good are medicine's new recipes?. J Law Med Ethics. 1995;23(1):47-8. [pmid: 7627301].
Not breast cancer in women.
Carder P J, Liston J C. Will the spectrum of lesions prompting a “B3” breast core biopsy increase the benign biopsy rate?. J Clin Pathol. 2003;56(2):133-8. [pmid: 12944564]. [pmcid: 1769892].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Carlson R W, Edge S B, Theriault R L, et al. NCCN: Breast cancer. [Review] [44 refs]. Cancer Control. 2001;8(6 Suppl 2):54-61. [pmid: 11760559].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Cataliotti L, Costa A, Daly P A, et al. Florence statement on breast cancer, 1998 forging the way ahead for more research on and better care in breast cancer. Eur J Cancer. 1999;35(1):14-5. [pmid: 10211082].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Catterall A. Guidelines for surgeons in the management of symptomatic breast disease in the United Kingdom. Eur J Surg Oncol. 1996;22(2):202. [pmid: 8608845].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Cell Markers And Cytogenetics Committees College Of American Pathologists. Clinical laboratory assays for HER-2/neu amplification and overexpression: quality assurance, standardization, and proficiency testing. [Review] [53 refs]. Arch Pathol Lab Med. 2002;126(7):803-8. [pmid: 12088449].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Cersosimo R J. Topotecan: a new topoisomerase I inhibiting antineoplastic agent. [Review] [85 refs]. Ann Pharmacother. 1998;32(12):1334-43. [pmid: 9876816].
Not breast cancer diagnosis or treatment.
Chaudhry R, Goel V, Sawka C. Breast cancer survival by teaching status of the initial treating hospital. [erratum appears in CMAJ 2001 May 1;164(9):1280]. CMAJ 2001;164(2):183–8.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Chen E A, Carlson G A, Coughlin B F, et al. Routine chest roentgenography is unnecessary in the work-up of stage I and II breast cancer. J Clin Oncol. 2000;18(20):3503-6. [pmid: 11032591].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Chui S Y, Lyerly H K. Disparities in breast carcinoma treatment in Asian/Pacific Islander women. A challenge to the provider. Cancer. 2002;95(11):2257-9. [pmid: 12436429].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Clarke M, Godwin J. Systematic reviews using individual patient data: a map for the minefields?. Ann Oncol. 1998;9(8):827-33. [pmid: 9789604].
Not breast cancer in women.
Cockburn J, Pit S, Zorbas H, et al. Investigating breast symptoms in primary care: enhancing concordance with current best advice. Cancer Detect Prev Suppl. 2001;25(5):407-13.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Coia L R, Hanks G E. Quality assessment in the USA: how the Patterns of Care study has made a difference. Semin Radiat Oncol. 1997;7(2):146-56. [pmid: 10717209].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Cole B F, Gelber R D, Goldhirsch A. A quality-adjusted survival meta-analysis of adjuvant chemotherapy for premenopausal breast cancer. International Breast Cancer Study Group. Stat Med. 1995;14(16):1771-84. [pmid: 7481209].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Coleman C. Building quality into comprehensive breast care: a practical approach. [Review] [81 refs]. Surg Oncol Clin N Am. 2000;9(2):319-37. [pmid: 10757847].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Coleman J. MCO trends. HMO quality report shows wide variability and improvement areas. Case Manager. 1998;9(2):38-43.
Not breast cancer diagnosis or treatment.
Conner-Spady B, Cumming C, Nabholtz J, et al. Responsiveness of the EuroQol in breast cancer patients undergoing high dose chemotherapy. Qual Life Res. 2001;10:479-86. [pmid: 11789549].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Consenso Nacional sobre Tratamiento del Cancer Mamario. [1st revision of the National Consensus on Breast Cancer Treatment]. [Spanish]. Ginecol Obstet Mex. 2002;70:349-60. [pmid: 12221911].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Contesso G, Mathieu M C, Guinebretiere J M. [Standardization of tests for the pathology of the breast]. [Review] [29 refs] [French]. Bull Cancer. 1996;83(12):1053-60. [pmid: 9116375].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Costa S D, Von Minckwitz G. Recommendations of the Sixth International Conference on Adjuvant Therapy of Breast Cancer, St. Gallen, 1998. Tumor Diagnostik und Therapie. 1998;19(1):1-4.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Cottu P H, Cuvier C, Espie M. High-dose adjuvant chemotherapy for breast cancer: State of the art. Forum (Genova). 2002;12(1):36-40. [pmid: 12634909].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Cox C E. Lymphatic mapping in breast cancer: combination technique. Ann Surg Oncol. 2001;8(9 Suppl):67S-70S. [pmid: 11776499].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Cox C E, Bass S S, Ku N N, et al. Sentinel lymphadenectomy: a safe answer to less axillary surgery?. Recent Results Cancer Res. 1998;152:170-9. [pmid: 9928556].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Cox C E, Bass S S, McCann C R, et al. Lymphatic mapping and sentinel lymph node biopsy in patients with breast cancer. Annu Rev Med. 2000;51:525-42. [pmid: 10774480].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Cox C E, Pendas S, Cox J M, et al. Guidelines for sentinel node biopsy and lymphatic mapping of patients with breast cancer. Ann Surg. 1998;227(5):645-51. [pmid: 9605656]. [pmcid: 1191339].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Cox C E, Salud C J, Cantor A, et al. Learning curves for breast cancer sentinel lymph node mapping based on surgical volume analysis. J Am Coll Surg. 2001;193(6):593-600. [pmid: 11768674].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Cramer S F. Error identification.[comment]. Am J Surg Pathol. 1999;23(5):610-13. [pmid: 10328096].
Not breast cancer in women.
Crowe P, Temple W. Management of the axilla in early breast cancer: is it time to change tack?. Aust N Z J Surg. 2000;70(4):288-96. [pmid: 10779062].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Cruse H, Winiarek. Quality and methods of developing practice guidelines. BMC Health Serv Res. 2002;2(1):1. [pmid: 11825346]. [pmcid: 65517].
Not breast cancer in women
Cuevas-Renaud C, De Jesus Sobrevilla-Calvo P, Almanza J. Development of a scale to measure psychosocial concerns of Mexican women with advanced cancer. Psychooncology. 2000;9:79-83. [pmid: 10668062].
Not breast cancer diagnosis or treatment.
Cuzick J, Stewart H, Rutqvist L, et al. Cause-specific mortality in long-term survivors of breast cancer who participated in trials of radiotherapy. J Clin Oncol. 1994;12(3):447-53. [pmid: 8120544].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
D'Orazio A, O'Shaughnessy J A, Jain V K, et al. The addition of carboplatin to trastuzumab/paclitaxel improves efficacy in HER2-overexpressing metastatic breast cancer. Clin Breast Cancer. 2003;3(6):378-80.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Damstra R J, Kaandorp C J E. Dutch Institute for Healthcare Improvement guideline ‘lymphedema’. Ned Tijdschr Geneeskd. 2003;147(14):648-52. [pmid: 12712647].
Not breast cancer in women.
Daniels N, Sabin J. Limits to health care: fair procedures, democratic deliberation, and the legitimacy problem for insurers. Philos Public Aff. 1997;26(4):303-50. [pmid: 11660435].
Not breast cancer in women.
Daniels N, Sabin J E. Last chance therapies and managed care. Pluralism, fair procedures, and legitimacy. Hastings Cent Rep. 1998;28(2):27-41. [pmid: 9589291].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
David M, Sindermann H, Junge K, et al. Topical treatment of skin metastases with 6% miltefosine solution (Miltex) in patients with breast cancer. A meta-analysis of 443 patients (Meeting abstract). Am J Clin Oncol. 1997;16.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Davidson N E, Levine M. Breast cancer consensus meetings: vive la difference?[comment]. J Clin Oncol. 2002;20(7):1719-20. [pmid: 11919226].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
de Bock G H, Vliet Vlieland T P, Hageman G C, et al. The assessment of genetic risk of breast cancer: a set of GP guidelines. Fam Pract. 1999;16(1):71-7. [pmid: 10321400].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
de Rijke J M, Schouten L J, Schouten H C, et al. Age-specific differences in the diagnostics and treatment of cancer patients aged 50 years and older in the province of Limburg, The Netherlands.[comment]. Ann Oncol. 1996;7(7):677-85. [pmid: 8905025].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
de Vries E G, Willemse P H. [Dutch Institute for Healthcare Improvement guideline, “Treatment of breast carcinoma”: important document but an open attitude to new “evidence” is necessary]. [Dutch]. Ned Tijdschr Geneeskd. 2002;146(45):2120-3. [pmid: 12474548].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Deb R A, Matthews P, Elston C W, et al. An audit of “equivocal” (C3) and “suspicious” (C4) categories in fine needle aspiration cytology of the breast. Cytopathology. 2001;12(4):219-26. [pmid: 11488870].
Not breast cancer in women.
Decruyenaere M, Evers-Kiebooms G, Claes E, et al. Psychosocial aspects of familial breast and ovarian cancer: psychological guidelines for genetic testing. Dis Markers. 1999;15(13):152-3. [pmid: 10595271].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Dee K E, Sickles E A. Medical audit of diagnostic mammography examinations: comparison with screening outcomes obtained concurrently. AJR Am J Roentgenol. 2001;176(3):729-33. [pmid: 11222214].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Demissie S, Silliman R A, Lash T L. Adjuvant tamoxifen: predictors of use, side effects, and discontinuation in older women. J Clin Oncol. 2001;19(2):322-8. [pmid: 11208822].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Dershaw D D. Equipment, technique, quality assurance, and accreditation for imaging-guided breast biopsy procedures. Radiol Clin North Am. 2000;38(4):773-89. [pmid: 10943277].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Diel I J. [Meta-analysis of prognostic significance of tumor cell demonstration in the bone marrow or: “Looking for an independent prognostic factor”]. [German]. Sonderb Z Strahlenther Onkol. 1999;175(1):45-6.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Dignam JJ. Efficacy of systemic adjuvant therapy for breast cancer in African-American and Caucasian women. J Natl Cancer Inst. 2001;Monographs.(30):36–43.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Dillman R O, Chico S. Radiologic tests after a new diagnosis of breast cancer. Eff Clin Pract. 2000;3(1):1-6. [pmid: 10788031].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Dittrich C. [Drug therapy of breast carcinoma]. [Review] [111 refs] [German]. Wien Med Wochenschr. 2000;150(4):72-86. [pmid: 10829307].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Dixon JM, Gregory K, Johnston S, et al. Breast cancer: non-metastatic. Clin Evid 2002;(7):1603–30.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Djulbegovic B, Hozo I, Lyman GH. Linking evidence-based medicine therapeutic summary measures to clinical decision analysis. MedGenMed. 2000;E6
Not breast cancer in women.
Doren M, Holst Th V, Distler W, et al. Role of raloxifene in the treatment of women at risk for osteoporosis - A commentary. Journal fur Menopause. 1999;6(4):18-20.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Dressler L G, Geradts J, Burroughs M, et al. Policy guidelines for the utilization of formalin-fixed, paraffin-embedded tissue sections: the UNC SPORE experience. University of North Carolina Specialized Program of Research Excellence. Breast Cancer Res Treat. 1999;58(1):31-9. [pmid: 10634516].
Not breast cancer in women.
Du X, Goodwin J S. Patterns of use of chemotherapy for breast cancer in older women: findings from Medicare claims data. J Clin Oncol. 2001;19(5):1455-61. [pmid: 11230491].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Du X, Freeman J L, Freeman D H, et al. Temporal and regional variation in the use of breast-conserving surgery and radiotherapy for older women with early-stage breast cancer from 1983 to 1995. J Gerontol A Biol Sci Med Sci. 1999;54(9):M474-8. [pmid: 10536651].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Dudley R A, Bowers L V, Luft H S. Reconciling quality measurement with financial risk adjustment in health plans. Jt Comm J Qual Improv. 2000;26(3):137-46. [pmid: 10709147].
Not breast cancer in women.
Dunning A M, Healey C S, Pharoah P D, et al. A systematic review of genetic polymorphisms and breast cancer risk. [Review] [67 refs]. Cancer Epidemiol Biomarkers Prev. 1999;8(10):843-54. [pmid: 10548311].
Not breast cancer diagnosis or treatment.
Dunsis A. Local impact of the NHMRC early breast cancer guidelines: where to from here?[comment]. Med J Aust. 1998;168(3):141. [pmid: 9484338].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Dunst J. [Effects of radiotherapy and surgery in early breast carcinoma. A meta-analysis of randomized trials]. [German]. Sonderb Z Strahlenther Onkol. 1996;172(7):405-6.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Dunst J. [Local recurrence of ductal in situ carcinoma of the breast]. [German]. Sonderb Z Strahlenther Onkol. 1999;175(7):348-9.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Dvorak M, Fisher C G. Clinical practice guidelines: breast cancer pain. CMAJ. 2002;167(1):14-5. [pmid: 12137069]. [pmcid: 116628].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Eccles D M, Evans D G, Mackay J. Guidelines for a genetic risk based approach to advising women with a family history of breast cancer. UK Cancer Family Study Group (UKCFSG). J Med Genet. 2000;37(3):203-9. [pmid: 10699057].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Edge S B. Breast cancer practice guidelines: evaluation and quality improvement. Acta Radiol Oncol. 1997;11(11A):151-4.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Edwards M J, Israel P Z. Beyond the credentialing and privileging controversy surrounding image-guided breast biopsy. The rationale for a national registry for quantifying outcomes. Bull Am Coll Surg. 1997;82(6):20-3. [pmid: 10168364].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Edwards M J, Staren E D, Fine R E. Consensus statement on fine-needle aspiration.[comment]. Am J Surg. 1997;174(4):386. [pmid: 9337158].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Eidtmann H, Jonat W. Treatment of breast carcinoma. Onkologe. 2002;8(Suppl 1):S11-4.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Eisinger F, Alby N, Bremond A, et al. [INSERM-FNCLCC collective expertise. Recommendations for medical management of women with genetic risk of developing breast and/or ovarian cancer]. [French]. Ann Genet. 1999;42(1):51-64. [pmid: 10214508].
Not breast cancer diagnosis or treatment.
Eisinger F, Alby N, Bremond A, et al. [Inserm ad hoc committee: Recommendations for the management of women with a genetic risk for developing cancer of the breast and/or the ovary]. [French]. Bull Cancer. 1999;86(3):307-13. [pmid: 10210766].
Not breast cancer diagnosis or treatment.
Eisinger F, Geller G, Burke W, et al. Cultural basis for differences between US and French clinical recommendations for women at increased risk of breast and ovarian cancer. Lancet. 1999;353(9156):919-20. [pmid: 10094000].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ellis I O, Dowsett M, Bartlett J, et al. Recommendations for HER2 testing in the UK. J Clin Pathol. 2000;53(12):890-2. [pmid: 11265171]. [pmcid: 1731136].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Elmore J G, Carney P A. Does practice make perfect when interpreting mammography?. J Natl Cancer Inst. 2002;94(5):321-3. [pmid: 11880465].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Engel J, Holzel D, Sauer H. Breast carcinoma: Recommendations for medical reports on guidance in the interdisciplinary process of care. Geburtshilfe Frauenheilkd. 1997;57(2):M26-8.
Not breast cancer diagnosis or treatment.
Engstrom C A. Clinical pathways and continuous quality improvement in ambulatory care for patients with advanced breast cancer. Innovations in Breast Cancer Care. 1999;1(2):41-3.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
ESMO. ESMO Minimum Clinical Recommendations for diagnosis, adjuvant treatment and follow-up of primary breast cancer. Ann Oncol. 2001;12(8):1047-8. [pmid: 11583179].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Espie M, Cottu P H. [Adjuvant treatment for breast cancer. Results of the consensus conference of Saint-Gall (February 2001)]. [French]. Gynecol Obstet Fertil. 2002;30(1):86-8. [pmid: 12043510].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Euhus D M, Peters G N, Leitch A M, et al. Validating the performance of the mammary sentinel lymph node team. J Surg Oncol. 2002;79(4):209-15. [pmid: 11920777].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Evers G C. [Clinical nursing research. New standards for quality assurance for nursing and patient]. [German]. Pflege. 2000;13(3):133-8. [pmid: 11194334].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Fallowfield L J. Quality of life measurement in breast cancer. J R Soc Med. 1993;86(1):10-2. [pmid: 8423565]. [pmcid: 1293814].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Fentiman I S, Christiaens M R. Quality assurance of surgery in clinical trials. Eur J Cancer. 1994;30A(2):136-7. [pmid: 8155383].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Fetscher S, Mertelsmann R. The clinical role of growth factors in the treatment of breast cancer. [Review] [36 refs]. Biomed Pharmacother. 1998;52(3):101-8. [pmid: 9755802].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Fietkau R. Influence of the timing of surgery and postoperative radiotherapy on treatment results. Strahlenther Onkol. 2000;176(10):452-7. [pmid: 11143526].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Fisher B, Anderson S, Redmond C K. Surgery for early breast cancer.[comment]. N Engl J Med. 1996;334(15):987-8. [pmid: 8596604].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Fitzgibbons P L, LiVolsi V A. Recommendations for handling radioactive specimens obtained by sentinel lymphadenectomy. Surgical Pathology Committee of the College of American Pathologists, and the Association of Directors of Anatomic and Surgical Pathology. Am J Surg Pathol. 2000;24(11):1549-51. [pmid: 11075858].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Fitzgibbons P L, Page D L, Weaver D, et al. Prognostic factors in breast cancer. College of American Pathologists Consensus Statement 1999. [Review] [167 refs]. Arch Pathol Lab Med. 2000;124(7):966-78. [pmid: 10888772].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Foord K, Guy R, Apthorp L, et al. Updated audit database for breast imaging/histopathology correlation. Clin Radiol. 2001;56(9):755-62. [pmid: 11585398].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Foy J E. Going the extra mile in patient care. An innovative program helps breast cancer patients navigate the healthcare system. Healthc Exec. 2002;17(6):66-7. [pmid: 12416349].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Frassica D A, Zellars R. Radiation oncology: The year in review. Curr Opin Oncol. 2002;14(6):594-9. [pmid: 12409648].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Freshwater M F. “Standard of care” for immediate breast reconstruction. Keisei Geka. 2001;107(6):1612.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Friedrichs K, Holzel F, Janicke F. Combination of taxanes and anthracyclines in first-line chemotherapy of metastatic breast cancer: an interim report. Eur J Cancer. 2002;38(13):1730-8. [pmid: 12175689].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Fries M H, Holt C, Carpenter I, et al. Guidelines for evaluation of patients at risk for inherited breast and ovarian cancer: recommendations of the Department of Defense Familial Breast/Ovarian Cancer Research Project. Mil Med. 2002;167(2):93-8. [pmid: 11873550].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Furst C J. Radiotherapy for cancer. Quality of life. Acta Oncol (Madr). 1996;35(Suppl):7141-8.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Gaisser A, Lindner UK. Consensus recommendations for adjuvant therapy of primary breast cancer. The 6th International Conference, 25–28 February 1998 in St. Gallen. Onkologe 1998;4(5):459–64.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Galvis C O, Raab S S, D'Amico F, et al. Pathologists' assistants practice: a measurement of performance. Am J Clin Pathol. 2001;116(6):816-22. [pmid: 11764069].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ganz P A. Breast cancer 2002: where do we stand?[comment]. CA Cancer J Clin. 2002;52(5):253-5. [pmid: 12363324].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Gazmararian J A, Lewis N. Health services research in the Prudential Health Care System. [Review] [5 refs]. Med Care Res Rev. 1996;53(Suppl):S82-91. [pmid: 10157722].
Not breast cancer diagnosis or treatment
Gelber RD, Bonetti M, Cole BF, et al. Quality of life assessment in the adjuvant setting: is it relevant? International Breast Cancer Study Group. [Review][23 refs]. Recent Results Cancer Res. 1998;152373–89.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Gelber R D, Cole B F, Goldhirsch A, et al. Adjuvant chemotherapy plus tamoxifen compared with tamoxifen alone for postmenopausal breast cancer: meta-analysis of quality-adjusted survival. Lancet. 1996;347(9008):1066-71. [pmid: 8602056].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ghersi D. Two drug combinations vs combinations of 3 or more cytotoxic drugs for metastatic breast cancer. Cochrane Database Syst Rev. 2003;1, 2003.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ghersi D. Single agent vs combination chemotherapy for metastatic breast cancer. Cochrane Database Syst Rev. 2003;1, 2003.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ghersi D. Platinum containing regimens for metastatic breast cancer. Cochrane Database Syst Rev. 2003;1, 2003.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ghersi D. Larger vs smaller dose of the same dru/s regimen for metastatic breast cancer. Cochrane Database Syst Rev. 2003;1, 2003.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ghersi D. Antitumour antibiotic containing regimens for metastatic breast cancer. Cochrane Database Syst Rev. 2003;1, 2003.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ghersi D. Addition of dru/s to a chemotherapy regimen for metastatic breast cancer. Cochrane Database Syst Rev. 2003;1, 2003.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Giard R W, Blok P. [Summary of the guideline ‘Sentinel Node Biopsy for Breast Cancer’]. [Dutch]. Ned Tijdschr Geneeskd. 2001;145(1):50-1. [pmid: 11257820].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Gibbs W W. What are obstacles to ideal care?. Sci Am. 1996;275(3):166. [pmid: 8984613].
Not breast cancer in women.
Gillis C R, Hole D J. Survival outcome of care by specialist surgeons in breast cancer: a study of 3786 patients in the west of Scotland. BMJ. 1996;312(7024):145-8. [pmid: 8973230].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ginsburg D. Chemotherapy for older women with node-positive breast cancer. CMAJ. 2001;165(5):525. [pmid: 11563200]. [pmcid: 81402].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Glasziou P P, Cole B F, Gelber R D, et al. Quality adjusted survival analysis with repeated quality of life measures. Stat Med. 1998;17(11):1215-29. [pmid: 9670411].
Not breast cancer in women.
Goel V. Health services research in breast cancer: background paper for a Canadian Breast Cancer Research Initiative workshop. Cancer Prev Control. 1998;2(4):173-8. [pmid: 10093634].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Goel V, Olivotto I, Hislop T G, et al. Patterns of initial management of node-negative breast cancer in two Canadian provinces. British Columbia/Ontario Working Group. CMAJ. 1997;156(1):25-35. [pmid: 9006561]. [pmcid: 1226853].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Going J J, Mallon E A, Leake R E, et al. What the clinician needs from the pathologist: evidence-based reporting in breast cancer. [Review] [153 refs]. Eur J Cancer. 2001;37(Suppl 7):S5-17. [pmid: 11888005].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Gold R, Caulfield T A, Ray P N. Gene patents and the standard of care. CMAJ. 2002;167(3):256-7. [pmid: 12186172]. [pmcid: 117472].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Goldhirsch A, Castiglione-Gertsch M. -Adjuvant systemic therapy of breast carcinoma-. [German]. Arch Gynecol Obstet. 1995;256(Suppl):S93-103. [pmid: 8619668].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Goldhirsch A, Wood W C, Senn H J, et al. IX. International consensus conference on primary treatment of breast cancer. [Review] [15 refs]. Recent Results Cancer Res. 1996;140:325-35. [pmid: 8787074].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Goodwin J S, Freeman J L, Mahnken J D, et al. Geographic variations in breast cancer survival among older women: implications for quality of breast cancer care. J Gerontol A Biol Sci Med Sci. 2002;57(6):M401-6. [pmid: 12023271].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Goolsby M J. Clinical practice guidelines. American College of Radiology appropriateness criteria. J Am Acad Nurse Pract. 2001;13(7):293-6. [pmid: 11930866].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Greely H T. Genetic testing for cancer susceptibility: challenges for creators of practice guidelines. Acta Radiol Oncol. 1997;11(11A):171-6.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Green M, Hortobagyi GN. Neoadjuvant chemotherapy for operable breast cancer. [Review][60 refs]. Acta Radiol Oncol 889;16(7):871–84.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Greer A L, Goodwin J S, Freeman J L, et al. Bringing the patient back in. Guidelines, practice variations, and the social context of medical practice. Int J Technol Assess Health Care. 2002;18(4):747-61. [pmid: 12602076].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Greinix H. [Place of high-dose therapy in breast cancer. Austrotransplant consensus conference 1999]. [German]. Wien Klin Wochenschr. 2000;112(13):601-3. [pmid: 11001746].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Grilli R. A shared effort toward better quality of care. The Consensus Conference on Breast Cancer Follow-up. Consensus Conference Organizing Committee. Ann Oncol. 1995;6(Suppl 2):5-9. [pmid: 8547201].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Grilli R, Lomas J. Evaluating the message: the relationship between compliance rate and the subject of a practice guideline. Med Care. 1994;32(3):202-13. [pmid: 8145598].
Not breast cancer in women.
Grilli R, Minozzi S, Tinazzi A, et al. Do specialists do it better? The impact of specialization on the processes and outcomes of care for cancer patients. [Review] [61 refs]. Ann Oncol. 1998;9(4):365-74. [pmid: 9636826].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Grilli R, Minozzi S, Tinazzi A, et al. A systematic review on the impact of specialization on process and outcomes of care for cancer patients [abstract]. Annu Meet Int Soc Technol Assess Health Care. 1995;1387.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Guthrie T H. Breast cancer litigation: an update with practice guidelines. Breast J. 1999;5(5):335-9. [pmid: 11348311].
Not breast cancer diagnosis or treatment.
Haas B K. The effect of managed care on breast cancer detection, treatment, and research. [Review] [36 refs]. Nurs Outlook. 1997;45(4):167-72. [pmid: 9279857].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hagen N A, Whylie B. Putting clinical practice guidelines into the hands of cancer patients. CMAJ. 1998;158(3):347-8. [pmid: 9484261]. [pmcid: 1228837].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hammond E H, Flinner R L. Clinically relevant breast cancer reporting: using process measures to improve anatomic pathology reporting. Arch Pathol Lab Med. 1997;121(11):1171-5. [pmid: 9372744].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hammond M E, Fitzgibbons P L, Compton C C, et al. College of American Pathologists Conference XXXV: solid tumor prognostic factors-which, how and so what? Summary document and recommendations for implementation. Cancer Committee and Conference Participants. [Review] [14 refs]. Arch Pathol Lab Med. 2000;124(7):958-65. [pmid: 10888771].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Harada Y, Ohuchi N, Ishida T, et al. Tumor markers in breast cancer. [Review] [31 refs] [Japanese]. Gan To Kagaku Ryoho. 2001;28(7):1035-40. [pmid: 11478135].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Harmer V. Benign breast disease. Nurs Times. 2001;97(47):32-3. [pmid: 11966260].
Not breast cancer in women.
Harris J R, Halpin-Murphy P, McNeese M, et al. Consensus Statement on postmastectomy radiation therapy. [Review] [3 refs]. Int J Radiat Oncol Biol Phys. 1999;44(5):989-90. [pmid: 10421530].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Hayes N A. Analyzing current practice patterns: lessons from Amgen's Project ChemoInsight. Oncol Nurs Forum. 2001;28(2 Suppl):11-6. [pmid: 11291207].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hebert-Croteau N, Brisson J, Latrielle J, et al. Compliance with consensus recommendations for the treatment of early stage breast carcinoma in elderly women. Cancer. 1999;85:1104-13. [pmid: 10091795].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Helbich T H, Buchberger W, Rudas M, et al. [Stereotactically and sonographically guided vacuum-assisted breast biopsy: a national consensus for Austria]. [German]. Rofo Fortschr Geb Rontgenstr Neuen Bildgeb Verfahr. 2002;174(4):517-22. [pmid: 12465616].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hellman S. Sun Valley summary. Consensus and action items Expedition Inspiration meeting 2000. Breast Cancer Res Treat. 2001;66(3):179-82. [pmid: 11804185].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hellriegel K P, Schulz K D. [After care of breast carcinoma patients--recommendations from the Berlin consensus conference]. [German]. Fortschr Med. 1996;114(5):43-5. [pmid: 8867474].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hellriegel K P, Schulz K D. Postoperative care of patients with carcinomas of the mamma - Recommendations of a Consensus Conference. Onkologie. 1996;19(1):94-6.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Henson D E, Oberman H A, Hutter R V. Practice protocol for the examination of specimens removed from patients with cancer of the breast: a publication of the Cancer Committee, College of American Pathologists. Members of the Cancer Committee, College of American Pathologists, and the Task Force for Protocols on the Examination of Specimens from Patients with Breast Cancer. Arch Pathol Lab Med. 1997;121(1):27-33. [pmid: 9111089].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hietanen P S. Measurement and practical aspects of quality of life in breast cancer. [Review] [40 refs]. Acta Oncol (Madr). 1996;35(1):39-42.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hill DJ, White VM, Giles GG, et al. Changes in the investigation and management of primary operable breast cancer in Victoria.[comment]. Med J Aust 114;161(2):110–1.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hillner B E, McDonald M K, Penberthy L, et al. Measuring standards of care for early breast cancer in an insured population. J Clin Oncol. 1997;15(4):1401-8. [pmid: 9193332].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hillner B E, Penberthy L, Desch C E, et al. Variation in staging and treatment of local and regional breast cancer in the elderly. Breast Cancer Res Treat. 1996;40(1):75-86. [pmid: 8888154].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hiraoka M, Mitsumori M, Shibuya K. Adjuvant radiation therapy following mastectomy for breast cancer. [Review] [37 refs]. Breast Cancer Res Treat. 2002;9(3):190-5.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hislop TG, Olivotto IA, Coldman AJ, et al. Variations in breast conservation surgery for women with axillary lymph node negative breast cancer in British Columbia. Can J Public Health. 1996;Revue Canadienne de Sante Publique. 87(6):390–4.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hoda S A, Rosen P P. Practical considerations in the pathologic diagnosis of needle core biopsies of breast. [Review] [13 refs]. Am J Clin Pathol. 2002;118(1):101-8. [pmid: 12109843].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hoffken K. Aromatase inhibitors of the 3rd generation in the therapy of breast carcinoma. Onkologe. 1999;5(1):58-67.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hoffman F A, Rheinstein P H, Houn F. The Mammography Quality Standards Act of 1992. Am Fam Physician. 1994;49(8):1965-70. [pmid: 8203325].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hogle WP. Pacing the standard of nursing practice in radiation oncology.[erratum appears in Clin J Oncol Nurs 2002 Mar-Apr;6(2):71]. Clin J Oncol Nurs 2001;5(6):253–6.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Holzel D, Engel J. [Value of centralization of patient management exemplified by breast carcinoma]. [German]. Sonderb Z Strahlenther Onkol. 2002;178(2):113-4.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hoppszallern S. FDA issues regulations on certification requirements for mammography facilities. Hosp Technol Ser. 1994;13(2):1-3. [pmid: 10135179].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hossfeld D K. [High-dosage treatment of breast cancer - against]. [German]. Dtsch Med Wochenschr. 2001;126(39):1092. [pmid: 11607859].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Houn F, Finder C. The Mammography Quality Standards Act and interventional mammography procedures. Bull Am Coll Surg. 1997;82(3):14-7. [pmid: 10166189].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Howell A. Tamoxifen versus the newer SERMs: what is the evidence?. [Review] [87 refs]. Ann Oncol. 2000;11(Suppl 3):255-65. [pmid: 11079150].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Howell D. Complete decongestive therapy for lymphedema following breast cancer treatment. Cochrane Database Syst Rev. 2003;1, 2003.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hughes K S, Barbarisi L J, Rossi R L, et al. Using continuous quality improvement (CQI) to improve the care of patients with breast cancer. Adm Radiol J. 1997;16(67):19-20. [pmid: 10170268].
Not breast cancer diagnosis or treatment.
Hunter R D. Increasing delays in starting radical radiotherapy treatment - The challenges. Clin Oncol (R Coll Radiol). 2003;15(2):39-40. [pmid: 12708708].
Not breast cancer in women.
Hurny C, Bernhard J, Coates A. Quality of life assessment in the International Breast Cancer Study Group: past, present, and future. [Review] [27 refs]. Recent Results Cancer Res. 1998;152:390-5. [pmid: 9928574].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Hynes D, Weaver F, Ippolito D, et al. Quality of care for mastectomy patients treated at VA hospitals: results from a national study[abstract]. Abstr Book Assoc Health Serv Res 199;16:352
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ikeda T, Jinno H, Masamura S, et al. Current status of adjuvant endocrine therapy for hormone responsive breast cancer. [Review] [14 refs] [Japanese]. Gan To Kagaku Ryoho. 2001;28(7):902-8. [pmid: 11478138].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
International Breast, Cancer Consensus, Conference. International consensus conference. Image-detected breast cancer: state of the art diagnosis and treatment. Breast J 2002;8(2):70–6.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Iredale R. Genetic service delivery for individuals at risk of familial breast cancer. Cochrane Database Syst Rev. 2003;1, 2003.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Iscoe N A, Goel V, Wu K, et al. Variation in breast cancer surgery in Ontario. CMAJ. 1994;150(3):345-52. [pmid: 8293375]. [pmcid: 1486167].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ishizaki T, Imanaka Y, Hirose M, et al. A first look at variations in use of breast conserving surgery at five teaching hospitals in Japan. Int J Qual Health Care. 2002;14(5):411-8. [pmid: 12389807].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Jacobson J S, Verret W J. Complementary and alternative therapy for breast cancer: the evidence so far. Cancer Pract. 2001;9(6):307-10. [pmid: 11879333].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
James M. Fraction size in radiation treatment for breast conservation in early breast cancer. Cochrane Database Syst Rev. 2003;1, 2003.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Jassem J, Pienkowski T, Pluzanska A, et al. Doxorubicin and paclitaxel versus fluorouracil, doxorubicin, and cyclophosphamide. J Clin Oncol. 2001;19:3441-2. [pmid: 11251000].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Jencks S F, Cuerdon T, Burwen D R, et al. Quality of medical care delivered to Medicare beneficiaries: a profile at state and national levels.[comment]. JAMA. 2000;284(13):1670-6. [pmid: 11015797].
Not breast cancer diagnosis or treatment.
Jerusalem G, Bours V, Fillet G. [Adjuvant treatment of breast cancer: meta-analysis and therapeutic recommendations]. [French]. Rev Med Liege. 2000;55(5):356-9. [pmid: 10941297].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Johnson T P, Ford L, Warnecke R B, et al. Effect of a National Cancer Institute Clinical Alert on breast cancer practice patterns. J Clin Oncol. 1994;12(9):1783-8. [pmid: 8083701].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Johnston S, Stebbing J. Breast cancer: metastatic. Clin Evid 2002;(7):1579–602.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Jonas S, Wild C, Schamberger C. [“Screening” in special situations. Assessing predictive genetic screening for hereditary breast and colorectal cancer]. [German]. Z Arztl Fortbild Qualitatssich. 2003;97(1):67-71. [pmid: 12669692].
Not breast cancer diagnosis or treatment.
Kaegi E. Unconventional therapies for cancer: 6. 714-X. Task Force on Alternative Therapeutic of the Canadian Breast Cancer Research Initiative. [Review] [22 refs]. CMAJ. 1998;158(12):1621-4. [pmid: 9645177]. [pmcid: 1229414].
Not breast cancer in women.
Kattlove H, Sherwood M, Dubois R. Development of a guideline for adjuvant treatment of early stage breast cancer: a new approach to blend evidence and expert panel opinion (Meeting abstract). Am J Clin Oncol. 1997;16.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Kaufmann M, Von Minckwitz G. [Report on the NIH Consensus Development Conference on Adjuvant Therapy of Breast Carcinoma]. [German]. Onkologie. 2001;24(2):190-2. [pmid: 11441303].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Kefford R, Tucker K, Friedlander M, et al. Cancer in the family. Part 2. [Review] [20 refs]. Aust Fam Physician. 1998;27(12):40-4. [pmid: 9503704].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Kelemen P R. Comprehensive review of sentinel lymphadenectomy in breast cancer. [Review] [111 refs]. Clin Breast Cancer. 2000;1(2):111-25. [pmid: 11899650].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Kell S H, Allison J J, Brown K C, et al. Measurement of mammography rates for quality improvement. Qual Manag Health Care. 1999;7(2):11-9. [pmid: 10346458].
Not breast cancer diagnosis or treatment.
Kennedy M J. Issues relating to the inclusion of high-dose chemotherapy in breast cancer treatment guidelines. Acta Radiol Oncol. 1997;11(11A):121-6.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Kerbrat P, Laguerre B, Lefeuvre C. [Post-treatment follow-up of breast cancer patients: comments on the guidelines of the American Society of Clinical Oncology (ASCO)]. [French]. Bull Cancer. 1997;84(10):991-2. [pmid: 9435803].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Khalkhali I, Diggles L E, Taillefer R, et al. Procedure guideline for breast scintigraphy. Society of Nuclear Medicine. Eur J Nucl Med. 1999;40(7):1233-5.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Kim J J. Part V. Adjuvant therapies for ductal carcinoma in situ. [Review] [42 refs]. Curr Probl Cancer. 2000;24(3):163-74. [pmid: 10919317].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Kimura M, Tominaga T. Outstanding problems with response evaluation criteria in solid tumors (RECIST) in breast cancer. Breast Cancer Res Treat. 2002;9(2):153-59.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Klabunde C N S. Quality assurance in follow-up and initial treatment for screening mammography programs in 22 countries. Int J Qual Health Care. 2002;14(6):449-61. [pmid: 12515331].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Knapick P. LCIS: is it cancer?[comment]. Am J Nurs. 2001;101(9):13. [pmid: 11559979].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Kodish E, Wiesner G L, Mehlman M, et al. Genetic testing for cancer risk: how to reconcile the conflicts.[comment]. JAMA. 1998;279(3):179-81. [pmid: 9438721].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Kohler P. [Experiences with a clinical cancer registry for radiotherapy]. [German]. Sonderb Z Strahlenther Onkol. 2001;177(5):259-63.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Kopans D B. Breast imaging and the standard of care for the symptomatic patient. Radiology. 1993;187(3):608-11. [pmid: 8234687].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Kouloulias V E. Quality assurance in radiotherapy. [Review] [46 refs]. Eur J Cancer. 2003;39(4):415-22. [pmid: 12957458].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Kreienberg R, Hiddemann W. New options in the treatment of breast cancer. Onkologe. 2000;6(Suppl 1):S1.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Kricker A, Armstrong B, Smith C, et al. An audit of breast cancer pathology reporting in Australia in 1995. Br J Cancer. 1999;80(34):563-8. [pmid: 10408867].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Kuhn T, Helms G, Kreienberg R. Surgical treatment of breast cancer: Current standards and new developments. Onkologe. 2002;8(8):837-46.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lagios M D. Pathologic practice standards for breast carcinoma: tumor size, reliable data, or miscues?[comment]. J Am Coll Surg. 2003;196(1):91-2. [pmid: 12517557].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lambird P A, Oneson R H. College of American Pathologists Foundation Conference VII: Ethical guidelines for biomedical technology development and application--the breast cancer paradigm: recommendations and summary. Arch Pathol Lab Med. 1994;118(11):1093-95. [pmid: 7979893].
Not breast cancer in women.
Landau D B, Laing R W. An audit of indications and techniques for supraclavicular fossa irradiation in early breast cancer in the United Kingdom. Clin Oncol (R Coll Radiol). 2000;12(3):172-8. [pmid: 10942334].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lantz P M, Richardson L C, Macklem D J, et al. Strategies for follow-up and treatment services in state breast and cervical cancer screening programs. Womens Health Issues. 1999;9(1):42-9. [pmid: 9949695].
Not breast cancer diagnosis or treatment.
Lantz P V, Zemencuk J K, Katz S J. Is mastectomy overused? A call for an expanded research agenda. Health Serv Res. 2002;37(2):417-31. [pmid: 12036001]. [pmcid: 1430371].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lawrence W D. Association of Directors of Anatomic and Surgical Pathology. ADASP recommendations for processing and reporting of lymph node specimens submitted for evaluation of metastatic disease. [Review] [36 refs]. Virchows Arch B Cell Pathol Incl Mol Pathol. 2001;439(5):601-3.
Not breast cancer in women.
Lazovich D A, White E, Thomas D B, et al. Underutilization of breast-conserving surgery and radiation therapy among women with stage I or II breast cancer. JAMA. 1991;266(24):3433-8. [pmid: 1688350].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lee-Feldstein A, Anton-Culver H, Feldstein P J. Treatment differences and other prognostic factors related to breast cancer survival. Delivery systems and medical outcomes. JAMA. 1994;271(15):1163-8. [pmid: 8151873].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Leitch AM, Meek AG, Smith RA, et al. American Cancer Society Lymphedema Workshop. Workgroup I: Treatment of the axilla with surgery and radiation--preoperative and postoperative risk assessment. [Review][8 refs]. Cancer. 1998;83(12 Suppl American):2877–9.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Leong SP. Selective sentinel lymph node mapping and dissection for breast cancer. [Review][60 refs]. Cancer Treat Res. 2002;11165–79.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Levine MN. Breast Cancer Chemotherapy Questionnaire. Gunnars B, Nygren P, Glimelius B. Assessment of quality of life during chemotherapy. Acta Oncol 2001;40:175–84.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lewis B E. Research at Fallon Community Health Plan. [Review] [13 refs]. Med Care Res Rev. 1996;53(Suppl):92-103. [pmid: 10157723].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lewis C. FDA sets higher standards for mammography. FDA Consum. 1999;33(1):13-7. [pmid: 10628310].
Not breast cancer diagnosis or treatment.
Lewis J A, Manne S L, DuHamel K N, et al. Social support, intrusive thoughts, and quality of life in breast cancer survivors. J Behav Med. 2001;24(3):231-45. [pmid: 11436544].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lickley H L. Primary breast cancer in the elderly. [Review] [86 refs]. Can J Surg. 1997;40(5):341-51. [pmid: 9336523].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Liebert B, Parle M, White K, et al. Establishing an evidence base for the specialist breast nurse: a model for Australian breast cancer care. Aust Health Rev. 2001;24(1):192-9. [pmid: 11357736].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lievens Y, Poortmans P, Van den Bogaert W. A glance on quality assurance in EORTC study 22922 evaluating techniques for internal mammary and medial supraclavicular lymph node chain irradiation in breast cancer. Radiother Oncol. 2001;60(3):257-65. [pmid: 11514005].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lillie-Blanton M. Mammography Quality Standards Act: X-ray quality improved, access unaffected, but impact on health outcomes unknown: testimony before the Subcommittee on Health and the Environment, Committee on Commerce, House of Representatives. Washington, DC: Committee on Commerce. 1998;10 p.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lin P P, Allison D C, Wainstock J, et al. Impact of axillary lymph node dissection on the therapy of breast cancer patients. J Clin Oncol. 1993;11(8):1536-44. [pmid: 8336192].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lind D S. Breast cancer testing: What is appropriate?. J Surg Oncol. 2002;81(3):111-2. [pmid: 12407719].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Linver M, Newman J. MQSA: the final rule. Radiol Technol. 1999;70(4):338-53. [pmid: 10101751].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Linver M N. Audits measure practice quality of mammography. Diagn Imaging (San Franc). 2000;22(7):57-61. [pmid: 11010308].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Look M P. Pooled analysis of uPA and PAI-1 for prognosis in primary breast cancer patients. EORTC Receptor and Biomarker Study Group. Int J Biol Markers. 2000;15(1):70-2. [pmid: 10763144].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Look M P, van Putten W L, Duffy M J, et al. Pooled analysis of prognostic impact of urokinase-type plasminogen activator and its inhibitor PAI-1 in 8377 breast cancer patients. J Natl Cancer Inst. 2002;94(2):116-28. [pmid: 11792750].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Loprinzi C L. It is now the age to define the appropriate follow-up of primary breast cancer patients.[comment]. J Clin Oncol. 1994;12(5):881-3. [pmid: 7989952].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Loprinzi C L, Thome S D. Understanding the utility of adjuvant systemic therapy for primary breast cancer.[comment]. J Clin Oncol. 2001;19(4):972-9. [pmid: 11181659].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lucci A, Kelemen P R, Miller C, et al. National practice patterns of sentinel lymph node dissection for breast carcinoma.[comment]. J Am Coll Surg. 2001;192(4):453-8. [pmid: 11294401].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lumley T, Simes R J, Gebski V, et al. Combining components of quality of life to increase precision and evaluate trade-offs. Stat Med. 2001;20(21):3231-49. [pmid: 11746315].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Lyon D. Cancer services. Appraising grace. Health Serv J. 2002;112(5812):26-7. [pmid: 12138743].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ma M, Bell J, Campbell S, et al. Breast cancer management: is volume related to quality? Clinical Advisory Panel. Br J Cancer. 1997;75(11):1652-9. [pmid: 9184182].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Macleod U, Ross S, Twelves C, et al. Primary and secondary care management of women with early breast cancer from affluent and deprived areas: retrospective review of hospital and general practice records.[comment]. BMJ. 2000;320(7247):1442-5. [pmid: 10827047]. [pmcid: 27387].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Madjar H, Rickard M, Jellins J, et al. IBUS guidelines for the ultrasonic examination of the breast. IBUS International Faculty. International Breast Ultrasound School. Eur J Ultrasound. 1999;9(1):99-102. [pmid: 10099171].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Mahajan D K, London S N. Mifepristone (RU486): a review. [Review] [80 refs]. Fertil Steril. 1997;68(6):967-76. [pmid: 9418681].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Mahoney L. Breast cancer guidelines. CMAJ. 1998;158(9):1131. [pmid: 9629094].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Mahoney L, Ali J, Burul C, et al. Guideline for the management of breast lumps.[comment]. Can J Surg. 1998;41(6):476-7. [pmid: 9854543].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Malin J L, Kahn K L, Adams J, et al. Validity of cancer registry data for measuring the quality of breast cancer care. J Natl Cancer Inst. 2002;94(11):835-44. [pmid: 12048271].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Malin J L, Schuster M A, Kahn K A, et al. Quality of breast cancer care: what do we know?. [Review] [87 refs]. J Clin Oncol. 2002;20(21):4381-93. [pmid: 12409338].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Malycha P, Tyson S. National breast surgery audit. Aust N Z J Surg. 2000;70(12):834-6. [pmid: 11167568].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Mandelblatt J S, Ganz P A, Kahn K L. Proposed agenda for the measurement of quality-of-care outcomes in oncology practice. [Review]. [71 refs]. J Clin Oncol. 1999;17(8):2614-22. [pmid: 10561329].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Mandelblatt J S, Hadley J, Kerner J F, et al. Patterns of breast carcinoma treatment in older women: patient preference and clinical and physical influences. Cancer. 2000;89(3):561-73. [pmid: 10931455].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Mannion R, Goddard M. Impact of published clinical outcomes data: case study in NHS hospital trusts. BMJ. 2001;323(7307):260-3. [pmid: 11485954]. [pmcid: 35346].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Martin R C, Edwards M J, Wong S L, et al. Practical guidelines for optimal gamma probe detection of sentinel lymph nodes in breast cancer: results of a multi-institutional study. For the University of Louisville Breast Cancer Study Group. Surgery. 2000;128(2):139-44. [pmid: 10922983].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Martinez MJ. Radioisotopes for metastatic bone pain. Cochrane Database Syst Rev. 2003;1, 2003.
Not breast cancer in women.
Mastboom W J B, Gerritsen J J G M, Koch P W A A, et al. The sentinel node procedure: Standard intervention in the surgical treatment of breast cancer (multiple letters). Ned Tijdschr Geneeskd. 1998;142(50):2754-5. [pmid: 10065240].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Mayer-Oakes S A, Barnes C. Developing indicators for the Medicare Quality Indicator System (MQIS): challenges and lessons learned. Jt Comm J Qual Improv. 1997;23(7):381-90. [pmid: 9257177].
Not breast cancer in women.
McCormick B, Mendenhall N P, Shank B M, et al. Local regional recurrence and salvage surgery. American College of Radiology. ACR Appropriateness Criteria. Radiology. 2000;215(Suppl):1181-92. [pmid: 11037542].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
McCrohan J, Morin R L. Proposition: federally mandated imaging standards (e.g., MQSA) serve the best interests of patients. Med Phys. 1998;25(6):811-3. [pmid: 9650167].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
McGlynn E A. Choosing chronic disease measures for HEDIS: conceptual framework and review of seven clinical areas. Manag Care Q. 1996;4(3):54-77. [pmid: 10159034].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
McGregor M. Clinical practice guidelines for the treatment of breast cancer [abstract]. Annu Meet Int Soc Technol Assess Health Care. 1999;15:60.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
McMasters K M, Giuliano A E, Ross M I, et al. Sentinel-lymph-node biopsy for breast cancer--not yet the standard of care. N Engl J Med. 1998;339(14):990-5. [pmid: 9753717].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
McQuay H J, Carroll D, Moore R A. Radiotherapy for painful bone metastases: a systematic review. [Review] [24 refs]. Clin Oncol (R Coll Radiol). 1997;9(3):150-4. [pmid: 9269545].
Not breast cancer in women.
McQuellon R P, Kimmick G, Hurt G J. Quality-of-life measurement in women with breast cancer. Breast J. 1997;3(4):178-86.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Meakins J L. The management of breast lumps.[comment]. Can J Surg. 1998;41(6):420. [pmid: 9854525].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Meguerditchian A N, Falardeau M, Martin G. Male breast carcinoma. [Review] [50 refs]. Can J Surg. 2002;45(4):296-302. [pmid: 12174988].
Not breast cancer in women.
Meijer W S. [Follow-up after oncological surgery].[comment]. [Dutch]. Ned Tijdschr Geneeskd. 2002;146(4):186-7. [pmid: 12532672].
Not breast cancer in women.
Meiser B, Eisenbruch M, Barlow-Stewart K, et al. Cultural aspects of cancer genetics: setting a research agenda. J Med Genet. 2001;38(7):425-9. [pmid: 11432959].
Not breast cancer diagnosis or treatment.
Mendenhall N P. Age-related variations in the use of axillary dissection. Int J Radiat Oncol Biol Phys. 2002;54(3):637-9. [pmid: 12377311].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Meterissian S. Breast cancer guidelines. CMAJ. 2002;166(10):1254. [pmid: 12041840]. [pmcid: 111073].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Meyskens F L, Jungi W F, Gerber M, et al. WHO consensus conference on diet and cancer. Members of the breast cancer panel. [Review] [21 refs]. Eur J Cancer Prev. 2000;9(3):213-6. [pmid: 10954261].
Not breast cancer diagnosis or treatment.
Mille D, Roy T, Carrere M O, et al. Economic impact of harmonizing medical practices: compliance with clinical practice guidelines in the follow-up of breast cancer in a French Comprehensive Cancer Center. J Clin Oncol. 2000;18(8):1718-24. [pmid: 10764432].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Miner T J, Shriver C D, Flicek P R, et al. Guidelines for the safe use of radioactive materials during localization and resection of the sentinel lymph node. Ann Surg Oncol. 1999;6(1):75-82. [pmid: 10030418].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Minter R M, Spengler K K, Topping D P, et al. Institutional validation of breast cancer treatment guidelines. J Surg Res. 2001;100(1):106-9. [pmid: 11516212].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Moller P, Apold J, Maehle L, et al. [European guidelines for health care in hereditary breast cancer]. [Norwegian]. Tidsskr Nor Laegeforen. 2000;120(6):726-7. [pmid: 10806889].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Monda L A. Mammography processor quality assurance. [Review] [28 refs]. Radiol Technol. 2002;74(1):46-68. [pmid: 12362534].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Moormeier J. Breast cancer in black women. [Review] [98 refs]. Ann Intern Med. 1996;124(10):897-905. [pmid: 8610920].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Moritz S, Bates T, Henderson S M, et al. Variation in management of small invasive breast cancers detected on screening in the former south east Thames region: observational study.[comment]. BMJ. 1997;315(7118):1266-72. [pmid: 9390053]. [pmcid: 2127781].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Morrow M. The local therapy for breast cancer as a model for evidence-based medical care. CA Cancer J Clin. 2002;8(4):288-94. [pmid: 12363326].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Morrow T, Siegel. Chemotherapy dose intensity determination as a quality of care measure for managed care organizations in the treatment of early-stage breast cancer. Am J Med Qual. 2002;17(6):218-24. [pmid: 12487337].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Mosconi P, Colozza M, De Laurentiis M, et al. Survival, quality of life and breast cancer. [Review] [36 refs]. Ann Oncol. 2001;12(Suppl 3):S15-9. [pmid: 11804378].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Moskowitz H, Barr J, Curry M. Improving quality of care in Connecticut--the example of breast health. Conn Med. 2001;65(9):569-70. [pmid: 11678060].
Not breast cancer diagnosis or treatment.
Motomura K, Komoike Y, Nagumo S, et al. Sentinel node biopsy to avoid axillary lymph node dissection in breast cancer. [Review] [32 refs]. Breast Cancer Res Treat. 2002;9(4):337-43.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Mourits M J, van der Zee A G, Willemse P H, et al. [Tamoxifen; wider indications, more frequent controls?]. [Dutch]. Ned Tijdschr Geneeskd. 2001;145(36):1766-7. [pmid: 11572184].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Moutardier V, Houvenaeghel G. [Breast cancer sentinel lymph node biopsy: learning curve and quality control measures]. [French]. Bull Cancer. 2001;88(12):1246-7. [pmid: 11792618].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Moyer A. Psychosocial outcomes of breast-conserving surgery versus mastectomy: a meta-analytic review.[erratum appears in Health Psychol 1997 Sep;16(5):442]. Health Psychol. 1997;16(3):284-98. [pmid: 9152708].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Nag S, Kuske R R, Vicini F A, et al. Brachytherapy in the treatment of breast cancer. [Review] [76 refs]. Acta Radiol Oncol. 2001;15(2):195-202.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Nagel G, Rohrig B, Hoyer H, et al. [A population-based study on variations in the use of adjuvant radiotherapy in breast cancer patients]. [German]. Sonderb Z Strahlenther Onkol. 2002;178(11):589-96.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Nakhleh R E, Jones B, Zarbo R J. Mammographically directed breast biopsies: a College of American Pathologists Q-Probes study of clinical physician expectations and of specimen handling and reporting characteristics in 434 institutions. Arch Pathol Lab Med. 1997;121(1):11-8. [pmid: 9111087].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Namer M. Therapeutic algorithm of metastatic breast cancer. Cahiers D'Oncologie. 1998;7(Suppl 6):S13-5.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Nassar B A, Ludman M D, Costa M T, et al. More on breast cancer guidelines.[comment]. CMAJ. 1998;158(11):1429-30. [pmid: 9629100].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
National Institutes of Health Consensus Development Conference: adjuvant therapy for breast cancer. Bethesda, Maryland, USA. November 1–3, 2000. [Proceedings][89 refs]. J Natl Cancer Inst Monogr 2001;(30):1–152.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Nattinger A B. Quality of care for breast cancer. Med Care. 2003;41(3):341-3. [pmid: 12618637].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Nattinger A B, Gottlieb M S, Hoffman R G, et al. Minimal increase in use of breast-conserving surgery from 1986 to 1990. Med Care. 1996;34(5):479-89. [pmid: 8614169].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Neven P, Vernaeve H. Guidelines for monitoring patients taking tamoxifen treatment. [Review] [55 refs]. Drug Saf. 2000;22(1):1-11. [pmid: 10647972].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Newman L. Report examines management of suspicious breast lesions. J Natl Cancer Inst. 2001;93(22):1683-4. [pmid: 11717326].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
NHS Centre, for Reviews, Dissemination. The effect of psychological interventions on anxiety and depression in cancer patients. Database of Abstracts of Reviews of Effectiveness. 2003;Issue 1, 2003.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
NHS Centre, for Reviews, Dissemination. Stereotactic radiosurgery for metastases to the brain. Database of Abstracts of Reviews of Effectiveness. 2003;Issue 1, 2003.
Not breast cancer in women.
NHS Centre, for Reviews, Dissemination. Psychotherapy groups and cancer patient survival. Database of Abstracts of Reviews of Effectiveness. 2003;Issue 1, 2003.
Not breast cancer in women.
NHS Centre, for Reviews, Dissemination. Stereotactic radiosurgery for metastases to the brain. Database of Abstracts of Reviews of Effectiveness. 2003;Issue 1, 2003.
Not breast cancer in women.
NHS Centre, for Reviews, Dissemination. Systematic review of cancer treatment programmes in remote and rural areas (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2003;Issue 1, 2003.
Not breast cancer in women.
NHS Centre, for Reviews, Dissemination. The effect of psychological interventions on anxiety and depression in cancer patients. Database of Abstracts of Reviews of Effectiveness. 2003;Issue 1, 2003.
Not breast cancer in women.
NHS Centre, for Reviews, Dissemination. Systematic review of cancer treatment programmes in remote and rural areas (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2003;Issue 1, 2003.
Not breast cancer diagnosis or treatment.
NHS Centre, for Reviews, Dissemination. Psychotherapy groups and cancer patient survival. Database of Abstracts of Reviews of Effectiveness. 2003;Issue 1, 2003.
Not breast cancer diagnosis or treatment.
NHS Centre, for Reviews, Dissemination. Stereotactic radiosurgery for metastases to the brain. Database of Abstracts of Reviews of Effectiveness. 2003;Issue 1, 2003.
Not breast cancer diagnosis or treatment.
Niederhuber J E. Seeking calmer waters in a sea of controversy.[comment]. Oncologist. 2002;7(3):172-3. [pmid: 12065785].
Not breast cancer diagnosis or treatment.
Nielsen D L, Kamby C. [Radiotherapy of primary breast cancer. An analysis of a systematic Cochrane review]. [Danish]. Ugeskr Laeger. 2003;165(3):219-21. [pmid: 12555702].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Nieweg O E, Tanis P J, de Vries J D, et al. [Summary of the guideline ‘Sentinel Lymph Node Biopsy for Breast Cancer’]. [Dutch]. Ned Tijdschr Geneeskd. 2001;145(1):51-2. [pmid: 11198968].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Noel G, Mazeron J-J. Regional radiotherapy increases neither morbidity nor mortality due to cardiac ischemia after mastectomy. Bull Cancer. 1999;86(12):968-9. [pmid: 10477383].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Noguchi M. A survival benefit from locoregional therapy: implication for Halsted's hypothesis. Breast Cancer Res Treat. 2002;9(1):3-5. [pmid: 12462388].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Noonan R. A risk management and quality improvement approach to delayed breast cancer diagnosis. Journal of Legal Nurse Consultants. 2002;13(2):14-7.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Noorani H, McGahan L, Hall A. Ethical, psycho-social and policy implications arising from predictivegenetic testing. I. Breast cancer [abstract]. Annu Meet Int Soc Technol Assess Health Care. 1993;1442.
Not breast cancer in women.
Nortier J W, Nooy M, Beex L. [Hormone replacement therapy after breast cancer].[comment]. [Dutch]. Ned Tijdschr Geneeskd. 1998;142(21):1229-30. [pmid: 9627461].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Nugent N, Hill A D, Casey M, et al. Safety guidelines for radiolocalised sentinel node resection. Ir J Med Sci. 2001;170(4):236-8. [pmid: 11918328].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
O'Higgins N, Linos D A, Blichert-Toft M, et al. European guidelines for quality assurance in the surgical management of mammographically detected lesions. [Review] [10 refs]. Eur J Surg Oncol. 1998;24(2):96-8. [pmid: 9591022].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Oates-Whitehead R. Methods of providing information to women making a decision about genetic screening and prophylactic surgery. Cochrane Database Syst Rev. 2003;1, 2003.
Not breast cancer diagnosis or treatment.
Oates-Whitehead R M. Wound drainage after axillary dissection for carcinoma of the breast. Cochrane Database Syst Rev. 2003;1, 2003.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ohkawa T, Kaneyasu Y, Karasawa K, et al. [Radiotherapy for breast cancers]. [Review] [17 refs] [Japanese]. Nippon Rinsho. 2000;58(Suppl):173-7. [pmid: 11025992].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Olbrisch RR. [Guidelines and quality assurance in plastic breast surgery]. [German]. Langenbecks Arch Chir Suppl Kongressbd. 1997;114173–7.
Not breast cancer in women.
Olivotto A, Coldman A J, Hislop T G, et al. Compliance with practice guidelines for node-negative breast cancer. J Clin Oncol. 1997;15(1):216-22. [pmid: 8996145].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Olivotto IA, Kan L, King S. Waiting for a diagnosis after an abnormal screening mammogram. SMPBC diagnostic process workgroup. Screening Mammography Program of British Columbia. Can J Public Health. 2000;Revue Canadienne de Sante Publique. 91(2):113–7.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Orell S R, Farshid G. False-positive reports in fine needle biopsy of breast lesions. [Review] [39 refs]. Pathology. 2001;33(4):428-36. [pmid: 11827408].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Osteen R T, Cady B, Chmiel J S, et al. 1991 national survey of carcinoma of the breast by the Commission on Cancer. J Am Coll Surg. 1994;178(3):213-9. [pmid: 8149010].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Osteen RT, Cady B, Friedman M, et al. Patterns of care for younger women with breast cancer. J Natl Cancer Inst. 1994;Monographs.(16):43–6.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ottevanger P B, Verhagen C A, Beex L V. Quality of adjuvant chemotherapy in primary breast cancer in a non-trial setting. A comprehensive cancer centre study. The Breast Cancer Group of the Dutch Comprehensive Cancer Centre East (IKO). Eur J Cancer. 1999;35(3):386-91. [pmid: 10448287].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ottosson-Lonn S, Wallgren A. [Reduced breast cancer mortality. Early treatment, as endocrine and cytostatic adjuvant therapy is effective].[comment]. [Review] [10 refs] [Swedish]. Lakartidningen. 1998;95(34):3494-7. [pmid: 9742830].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Overgaard M. Overview of randomized trials in high risk breast cancer patients treated with adjuvant systemic therapy with or without postmastectomy irradiation. Semin Radiat Oncol. 1999;9(3):292-9. [pmid: 10378969].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Page D L. Breast cancer pathology reporting practice and guidelines. J Am Coll Surg. 2003;196(1):89-90. [pmid: 12517556].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Paik S, Bryant J, Tan-Chiu E, et al. Real-world performance of HER2 testing--ational Surgical Adjuvant Breast and Bowel Project experience. J Natl Cancer Inst. 2002;94(11):852-4. [pmid: 12048273].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Paridaens R, Biganzoli L, Bruning P, et al. Paclitaxel versus doxorubicin as first-line single-agent chemotherapy for metastatic breast cancer: A European organization for research and treatment of cancer randomized study with cross-over. J Clin Oncol. 2000;18:724-33. [pmid: 10673513].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Parker L S, Majeske R A. Standards of care and ethical concerns in genetic testing and screening. [Review] [41 refs]. Clin Obstet Gynecol. 1996;39(4):873-84. [pmid: 8934037].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Parle M, Gallagher J, Gray C, et al. From evidence to practice: factors affecting the specialist breast nurse's detection of psychological morbidity in women with breast cancer. Psychooncology. 2001;10(6):503-10. [pmid: 11747062].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Patel R, Smith D, Reid I. Delay in diagnosis in breast cancer.[comment]. Lancet. 1999;353(9170):2154-5. [pmid: 10382716].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Payne R, Medina E, Hampton J W. Quality of life concerns in patients with breast cancer: evidence for disparity of outcomes and experiences in pain management and palliative care among African-American women. [Review] [38 refs]. Cancer. 2003;97(1 Suppl):311-7. [pmid: 12491494].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Pearson M L, Ganz P A, McGuigan K, et al. The case identification challenge in measuring quality of cancer care. [Review] [66 refs]. J Clin Oncol. 2002;20(21):4353-60. [pmid: 12409335].
Not breast cancer in women.
Penault-Llorca F, Jacquemier J, Le Doussal V, et al. Quality challenge for immunohistochemistry: Example of the ERBB-2 status in breast cancer. Ann Pathol. 1999;19(4):280-2. [pmid: 10544761].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Perry B. Quality improvement in a managed care organization from a medical director's perspective: an interview with Bruce Perry. Interview by Douglas Roblin. Jt Comm J Qual Improv. 2000;26(10):601-10. [pmid: 11042823].
Not breast cancer in women.
Pfisterer J, Hilpert F, Budach W, et al. Treatment of non-invasive breast cancer. Onkologe. 2002;8(8):826-31.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Picardi N. [Guideline concepts of the present-day surgery in breast cancer]. [Review] [71 refs] [Italian]. Ann Ital Chir. 1999;70(3):321-33. [pmid: 10692795].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Piccart M. Closing remarks and treatment guidelines. [Review] [11 refs]. Eur J Cancer. 2001;37(Suppl 1):30-3. [pmid: 11888004].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Piccart M J, van de V, Straehle C. The EORTC strategy for the early 2000's. Clin Breast Cancer. 2000;1(2):166-7. [pmid: 11899656].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Pierce L J, Lichter A S. Defining the role of post-mastectomy radiotherapy: the new evidence. Acta Radiol Oncol. 1011;10(7):991-1002.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Pinson NY. The breast and cervical cancer treatment program: accepting inequality for undocumented women?. Berkeley Women's Law Journal. 2002;17122–36.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Polednak A P. Frequency of prophylactic contralateral mastectomy among breast cancer patients. J Am Coll Surg. 2001;192(6):804-5. [pmid: 11400978].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Polgar C, Fodor J, Major T, et al. Radiotherapy confined to the tumor bed following breast conserving surgery: Current status, controversies, and future prospects. Sonderb Z Strahlenther Onkol. 2002;178(11):597-606.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Porpiglia M, Genta F, Vicelli R, et al. The role of aromatase inhibitors in the treatment of breast neoplasms: An evaluation of clinical efficacy and the tolerability profile. Minerva Ginecol. 2002;54(2):115-31. [pmid: 12032450].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Port E R, Fey J, Gemignani M L, et al. Reoperative sentinel lymph node biopsy: a new option for patients with primary or locally recurrent breast carcinoma. J Am Coll Surg. 2002;195(2):167-72. [pmid: 12168962].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Porter G A, McMulkin H, Lovrics P J. Sentinel lymph node biopsy in breast cancer: Canadian practice patterns. Ann Surg Oncol. 2003;10(3):255-60. [pmid: 12679310].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Potosky A L, Merrill R M, Riley G F, et al. Breast cancer survival and treatment in health maintenance organization and fee-for-service settings.[comment]. J Natl Cancer Inst. 1997;89(22):1683-91. [pmid: 9390537].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Prechtel K, Prechtel D. [Current standards for the diagnosis of breast carcinoma in routine practice]. [German]. Pathologe. 2001;22(4):281-4. [pmid: 11490943].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Purushotham A D, Pain S J, Miles D, et al. Variations in treatment and survival in breast cancer. [Review] [61 refs]. Lancet Oncol. 2001;2(12):719-25. [pmid: 11902513].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Pyrhonen S, Ellmen J, Vuorinen J, et al. Meta-analysis of trials comparing toremifene with tamoxifen and factors predicting outcome of antiestrogen therapy in postmenopausal women with breast cancer. Breast Cancer Res Treat. 1999;56(2):133-43. [pmid: 10573106].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Quinn C M, Lioe T. Essential parameters in breast cancer: histopathology reporting guidelines. Ir Med J. 2002;95(1):8-11. [pmid: 11928793].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Quintana Vargas I, Belles Medall D, Martinez Romero G, et al. Adjuvant chemotherapy for breast cancer: Inter-centre variability and compliance with current guidelines. Farm Hosp. 2002;26(4):219-23.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Raabe N K, Kaaresen R, Fossa S D. Analysis of adjuvant treatment in postmenopausal patients with stage II invasive breast carcinoma--a pattern of care study and quality assurance of 431 consecutive patients in Oslo 1980-1989. Acta Oncol (Madr). 1997;36(3):255-60.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Randal J. Taxane evidence inconclusive in adjuvant setting. J Natl Cancer Inst. 2001;93(3):168-9. [pmid: 11752003].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Rankin N, Newell S, Sanson-Fisher R, et al. Consumer participation in the development of psychosocial clinical practice guidelines: opinions of women with breast cancer. Eur J Cancer Care (Engl). 2000;9(2):97-104. [pmid: 11261017].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ravaioli A, Pasini G, Polselli A, et al. Staging of breast cancer: new recommended standard procedure. Breast Cancer Res Treat. 2002;72(1):53-60. [pmid: 12000220].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Recht A, Rutgers EJ, Fentiman IS, et al. The fourth EORTC DCIS Consensus meeting (Chateau Marquette, Heemskerk, The Netherlands, 23–24 January 1998)--conference report. [Review][42 refs]. Eur J Cancer 1998;34(11):1664–9.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Redman S, Reeve T S. Breast cancer guidelines in action. Med J Aust. 2000;172(5):196-7. [pmid: 10776386].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Rees C E, Bath P A. The information needs and source preferences of women with breast cancer and their family members: a review of the literature published between 1988 and 1998. [Review] [54 refs]. J Adv Nurs. 2000;31(4):833-41. [pmid: 10964184].
Not breast cancer diagnosis or treatment.
Reid R L. More on breast cancer guidelines. CMAJ. 1998;158(11):1426-30. [pmid: 9780969].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Reilly J, Mitchell A, Blue J, et al. Breast cancer audit: adapting national audit frameworks for local review of clinical practice. Health Bull (Edinb). 2001;59(1):60-2. [pmid: 12811914].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Rew D A. Towards a scientific basis for oncoplastic breast surgery. Eur J Surg Oncol. 2003;29(2):105-6. [pmid: 14602497].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Rhodes A, Jasani B, Balaton A J, et al. Immunohistochemical demonstration of oestrogen and progesterone receptors: correlation of standards achieved on in house tumours with that achieved on external quality assessment material in over 150 laboratories from 26 countries. J Clin Pathol. 2000;53(4):292-301. [pmid: 11041059]. [pmcid: 1731173].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Richards M A, Wolfe C D, Tilling K, et al. Variations in the management and survival of women under 50 years with breast cancer in the South East Thames region. Br J Cancer. 1996;73(6):751-7. [pmid: 8611375].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ridner S H. Breast cancer lymphedema: pathophysiology and risk reduction guidelines. Oncol Nurs Forum. 2002;29(9):1285-93. [pmid: 12370698].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Riedinger J M, Gauchez A S. Tumor markers in breast cancer management, clinical practice and recommendations. J Radiol Electrol Med Nucl. 2002;26(1):22-30.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Riemsma R P, Pattenden J, Bridle C, et al. A systematic review of the effectiveness of interventions based on a stages-of-change approach to promote individual behaviour change. Health Technol Assess. 2002;6(24):1-231. [pmid: 12433313].
Not breast cancer in women.
Riley G F, Potosky A L, Klabunde C N, et al. Stage at diagnosis and treatment patterns among older women with breast cancer: an HMO and fee-for-service comparison. JAMA. 1999;281(8):720-6. [pmid: 10052442].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ring A, Head J. 25th Annual San Antonio Breast Cancer Symposium, San Antonio, Texas, USA, 10–14 December 2002 update on clinical research. Breast Cancer Res Treat 2003;5(2):113–6.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Robert G, Milne R. A Delphi study to establish national cost-effectiveness research priorities for positron emission tomography. Eur J Radiol. 1999;30(1):54-60. [pmid: 10389013].
Not breast cancer diagnosis or treatment.
Robinson R G, Preston D F, Schiefelbein M, et al. Strontium 89 therapy for the palliation of pain due to osseous metastases. [Review] [38 refs]. JAMA. 1995;274(5):420-4. [pmid: 7542352].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Roche H, Dalenc F, Gladieff L. Optimal use of anthracyclines and taxanes: Combination or sequential treatment?. Cahiers D'Oncologie. 2002;4(1):69-74.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Rockson S G, Miller L T, Senie R, et al. American Cancer Society Lymphedema Workshop. Workgroup III: Diagnosis and management of lymphedema. [Review] [8 refs]. Cancer. 1998;83(12 Suppl American):2882-5. [pmid: 9874417].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Roetzheim R G, Chirikos T N. Breast cancer detection and outcomes in a disability beneficiary population. J Health Care Poor Underserved. 2002;13(4):461-76. [pmid: 12407963].
Not breast cancer diagnosis or treatment.
Rogers P B, Plowman P N. Regional node radiotherapy for breast cancer. Lancet. 1998;351(9099):374. [pmid: 9652651].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Rollins G. Amid controversy, task force recommends more widespread use of mammograms. Rep Med Guidel Outcomes Res. 1995;13(6):1-2.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Rollins G. Study finds significant differences in breast cancer treatment. Rep Med Guidel Outcomes Res. 2001;12(4):1-2. [pmid: 12402942].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Rollins G. Consensus statement outlines adjuvant treatment options for women with breast cancer. Rep Med Guidel Outcomes Res. 2001;12(2):9-10. [pmid: 12402942].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Rollins G. Landmark hormone replacement therapy study stopped after finding more harms than benefits. Rep Med Guidel Outcomes Res. 2002;13(15):5-7. [pmid: 12747368].
Not breast cancer in women.
Romain S, Spyratos F, Goussard J, et al. Improvement of quality control for the assessment of steroid receptors: Distribution of values in more than 40,000 breast cancers. Immuno-Analyse et Biologie Specialisee. 1997;12(1):21-3.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Rosalki J R, Karp S J. Guidance on the creation of evidence-linked guidelines for COIN. Clin Oncol (R Coll Radiol). 1999;11(1):28-32. [pmid: 10194583].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Rosalki J R, Karp S J. The COIN workstation: state of the future art.[comment]. Clin Oncol (R Coll Radiol). 1999;11(1):15-27. [pmid: 10194583].
Not breast cancer in women.
Rose V L. NCCN and ACS collaborate on a patient's version of the NCCN practice guidelines for breast cancer. National Comprehensive Cancer Network. American Cancer Society. Am Fam Physician. 1999;60(7):2169-70. [pmid: 10569516].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Roumen R M. [Prognostic benefits evaluated: new guidelines for systemic adjuvant therapy for axillary node-negative breast cancer vs. implementation of sentinel node biopsy procedure]. [Dutch]. Ned Tijdschr Geneeskd. 2000;144(21):980-4. [pmid: 11031679].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Roumen R M, Pijpers H J, Thunnissen F B, et al. [Summary of the guideline ‘Sentinel node biopsy in breast cancer.’ Dutch Work Group ‘Sentinel Node Biopsy for Breast Cancer’].[comment]. [Dutch]. Ned Tijdschr Geneeskd. 2000;144(39):1864-7. [pmid: 11031679].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ruers T J, Roumen R M. [The sentinel node biopsy in patients with breast cancer: recommendations for the introduction of this procedure. Dutch Working Group Sentinel Node Biopsy in Breast Cancer]. [Dutch]. Ned Tijdschr Geneeskd. 1998;142(41):2237-40. [pmid: 9864498].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ruether A. Enzyme therapy in oncology. Cochrane Database Syst Rev. 2003;1, 2003.
Not breast cancer in women.
Runowicz C D, Passik S D, Hann D, et al. American Cancer Society Lymphedema Workshop. Workgroup II: Patient education--pre-and posttreatment. Cancer. 1998;83(12 Suppl American):2880-1. [pmid: 9874416].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Rust S. Improvement of women's breast health services. J Ambul Care Manage. 2003;26(3):199-208. [pmid: 12856499].
Not breast cancer diagnosis or treatment.
Rutgers E J, Tuut M K. [CBO guideline ‘Breast cancer: screening and diagnosis’]. [Dutch]. Ned Tijdschr Geneeskd. 2001;145(3):115-9. [pmid: 11206120].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Rutgers E J, Nortier J W, Beex I, et al. [Tamoxifen; wider indications, more frequent controls?]. [Dutch]. Ned Tijdschr Geneeskd. 2001;145(36):1766-7. [pmid: 11589197].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Rutqvist L E. Breast cancer. Acta Oncol (Madr). 1996;35(Suppl 7):54-63.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Sabel M, Aichinger U, Schulz-Wendtland R, et al. Full-field digital mammography: Physical principles and clinical aspects. Rontgenpraxis. 1999;52(56):171-7. [pmid: 10574025].
Not breast cancer in women.
Sack H. [Breast-conserving treatment compared to mastectomy in early breast carcinoma: a meta-analysis of 10-year survival]. [German]. Sonderb Z Strahlenther Onkol. 1998;174(1):47-8.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Sainsbury R, Rider L, Smith A, et al. Does it matter where you live? Treatment variation for breast cancer in Yorkshire. The Yorkshire Breast Cancer Group. Br J Cancer. 1995;71(6):1275-8. [pmid: 7779723].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Sakamoto J, Nakakawaji K, Uchida T, et al. [Fourth Early Breast Cancer Trialists' Collaborative Group meeting in Oxford--meta-analysis of early breast cancer clinical trials]. [Japanese]. Gan To Kagaku Ryoho. 1996;23(3):373-8. [pmid: 8978805].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Sanders G D, Nease R F, Owens D K. Publishing web-based guidelines using interactive decision models. [Review] [106 refs]. J Eval Clin Pract. 2001;7(2):175-89. [pmid: 11489042].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Santen R, Pritchard K, Burger H. The consensus conference on treatment of estrogen deficiency symptoms in women surviving breast cancer. Obstet Gynecol Surv. 1998;53(10 Suppl):1-83. [pmid: 9793942].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Sauer H. [New after-care guidelines in breast carcinoma]. [Review] [14 refs] [German]. Geburtshilfe Frauenheilkd. 1996;56(9):M141-3. [pmid: 8991837].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Sauer R. [The effect of local control on overall survival after the breast-conserving therapy of breast carcinoma]. [German]. Sonderb Z Strahlenther Onkol. 1996;172(4):181-5.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Sauer R, Schulz K D, Hellriegel K P, et al. [Radiation therapy after mastectomy--interdisciplinary consensus puts and end to a controversy. German Society of Senology]. [Review] [64 refs] [German]. Sonderb Z Strahlenther Onkol. 2001;177(1):1-9.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Scharl A, Kaufmann M. Sentinel lymph node biopsy in carcinoma of the breast - Standard of care for the next millennium?. Geburtshilfe Frauenheilkd. 1999;59(4):139-41.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Schmid L, Delbruck H, Bartsch H, et al. [Structural quality of oncologic rehabilitation. Viewpoint of the Professional Committee of Rehabilitation, After-care and Social Medicine of the German Cancer Society]. [German]. Rehabilitation. 2000;39(6):350-4. [pmid: 11189779].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Schmidt F, Hartwagner K A, Spork E B, et al. Medical audit after 26,711 breast imaging studies: improved rate of detection of small breast carcinomas (classified as Tis or T1a,b). Cancer. 1998;83(12):2516-20. [pmid: 9874457].
Not breast cancer diagnosis or treatment.
Schmidt-Forgber I. [Effect of treatment delay on survival in patients with breast cancer: a systematic review]. [German]. Sonderb Z Strahlenther Onkol. 2000;176(5):243.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Schofield M J, Walkom S, Sanson-Fisher R. Patient-provider agreement on guidelines for preparation for breast cancer treatment. Behav Med. 1997;23(1):36-45. [pmid: 9201429].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Schwartz G F. Consensus Conference on the Classification of Ductal Carcinoma in situ. The current treatment of ductal carcinoma in situ. Breast J. 2001;7(5):308-10. [pmid: 11906440].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Schwartz GF, Giuliano AE, Veronesi U, et-al. Proceedings of the consensus conference on the role of sentinel lymph node biopsy in carcinoma of the breast, April 19–22, 2001, Philadelphia, Pennsylvania. Cancer 2002;94(10):2542–51.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Schwartz GF, Giuliano AE, Veronesi U, et-al. Proceedings of the consensus conference on the role of sentinel lymp node biopsy in carcinoma of the breast April 19–22, 2001, Philadelphia, PA, USA. Breast Cancer Res Treat 2002;11(4):362–73.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Schwartz G F, Solin L J, Olivotto I A, et al. [The consensus conference on the treatment of in situ ductal carcinoma of the breast, April 22–25, 1999]. [French]. Bull Cancer. 2000;87(6):499-506. [pmid: 10903791].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Schwartz G F, Solin L J, Olivotto I A, et al. Consensus Conference on the Treatment of In Situ Ductal Carcinoma of the Breast, April 22–25, 1999. Cancer. 2000;88(4):946-54. [pmid: 10679665].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Segal M. Mammography facilities must meet quality standards. FDA Consum. 1994;28(2):8-12. [pmid: 10132985].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Sener S F. Sentinel lymphadenectomy for breast cancer. A standard of surgical care?. Cancer Pract. 2000;8(4):195-6. [pmid: 11898259].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Seroussi B, Bouaud J, Antoine EC. Users' evaluation of OncoDoc, a breast cancer therapeutic guideline delivered at the point of care. Proc AMIA Symp 1999, Annual Symposium 384–9.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Seroussi B, Bouaud J, Antoine E C. ONCODOC: a successful experiment of computer-supported guideline development and implementation in the treatment of breast cancer. Artif Intell Med. 2001;22(1):43-64. [pmid: 11259883].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Shan K, Lincoff A M, Young J B. Anthracycline-induced cardiotoxicity. [Review] [146 refs]. Ann Intern Med. 1996;125(1):47-58. [pmid: 8644988].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Shannon J, Douglas-Jones A G, Dallimore N S. Conversion to core biopsy in preoperative diagnosis of breast lesions: is it justified by results?. J Clin Pathol. 2001;54(10):762-5. [pmid: 11577122]. [pmcid: 1731291].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Shimozuma K. Assessment of quality of life in breast cancer patients. [Review] [9 refs] [Japanese]. Nippon Rinsho. 2000;58(Suppl):497-501. [pmid: 11026040].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Shimozuma K. Quality of life assessment. [Review] [26 refs]. Breast Cancer Res Treat. 2002;9(2):100-6.
Not breast cancer diagnosis or treatment.
Shivers S, Cox C, Leight G, et al. Final results of the Department of Defense multicenter breast lymphatic mapping trial. Ann Surg Oncol. 2002;9(3):248-55. [pmid: 11923131].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Siebert W. Quality - The doctor as risk factor. Gynakol Prax. 2002;26(4):597-8.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Siegelmann-Danieli N, Ron I, Kaufman B, et al. Hormone replacement therapy in breast cancer survivors: the Israeli Society for Clinical Oncology and Radiotherapy policy letter. [Hebrew]. Harefuah. 1996;141(11):994-6.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Silliman R A, Lash T L. Do variations in breast cancer care matter?[comment]. Med Care. 2002;40(3):177-80. [pmid: 11880790].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Silliman R A, Troyan S L, Guadagnoli E, et al. The impact of age, marital status, and physician-patient interactions on the care of older women with breast carcinoma. Cancer. 1997;80(7):1326-34. [pmid: 9317187].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Silverstein M J. State-of-the-art breast units--a possibility or a fantasy? A comment from the US. [comment]. Eur J Cancer. 2000;36(18):2283-5. [pmid: 11094299].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Simmons J. AAHP identifies best practices for breast cancer. Qual Lett Healthc Lead. 1998;10(9):13-4. [pmid: 10185745].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Singh N, Wells C A. Assessment of accuracy in breast cytology. Cytopathology. 2001;12(4):211-8. [pmid: 11488869].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Singh-Ranger G, Mokbel K. American Society of Clinical Oncology. Advances in breast oncology: the 2002 ASCO meeting. Curr Med Res Opin. 2002;18(7):401-6. [pmid: 12487506].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Singletary S E, Allred C, Ashley P, et al. Revision of the American Joint Committee on Cancer staging system for breast cancer. J Clin Oncol. 2002;20(17):3628-36. [pmid: 12202663].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Skrutkowska M, Weijer C. Do patients with breast cancer participating in clinical trials receive better nursing care?[comment]. Oncol Nurs Forum. 1997;24(8):1411-6. [pmid: 9380596].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Sledge G W. Chemotherapy for breast cancer: What's new? What's useful?. Clin Breast Cancer. 2003;3(6):367. [pmid: 14715104].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Sloane J P, Amendoeira I, Apostolikas N, et al. Consistency achieved by 23 European pathologists from 12 countries in diagnosing breast disease and reporting prognostic features of carcinomas. European Commission Working Group on Breast Screening Pathology. Virchows Arch B Cell Pathol Incl Mol Pathol. 1999;434(1):3-10.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Smith T J, Hillner B E. Ensuring quality cancer care by the use of clinical practice guidelines and critical pathways. [Review] [51 refs]. J Clin Oncol. 2001;19(11):2886-97. [pmid: 11387362].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Smith T J, Somerfield M R. The ASCO experience with evidence-based clinical practice guidelines. Acta Radiol Oncol. 1997;11(11A):223-7.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Sorscher S, Levonian P. BCRA 1 testing guidelines for high-risk patients. J Clin Oncol. 1997;15(4):1711. [pmid: 9213589].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Spillane A J, Sacks N P. Role of axillary surgery in early breast cancer: review of the current evidence. Aust N Z J Surg. 2000;70(7):515-24. [pmid: 10901581].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Sprangers M A, Cull A, Groenvold M, et al. The European Organization for Research and Treatment of Cancer approach to developing questionnaire modules: an update and overview. EORTC Quality of Life Study Group. Qual Life Res. 1998;7(4):291-300. [pmid: 9610213].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Stanfill P H, Weber D. A review of breast conservation in Columbia/HCA healthcare facilities. J Oncol Manag. 1998;7(5):19-23. [pmid: 10187173].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Staniszewska M A, Papierz S. [Mammography in Lodz--doses and conditions of diagnostic devices]. [Polish]. Med Pr. 2002;53(4):307-310. [pmid: 12474409].
Not breast cancer in women.
Stebbing J J, Gaya A. The evidence-based use of induction chemotherapy in breast cancer. [Review] [66 refs]. Breast Cancer Res Treat. 2001;8(1):23-37.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Steene Jan V, Storme Gu. Meta-Analysis of Breast Cancer Surgery Trials Confirms Significant Factors for Overall Survival Benefit Due to Adjuvant Radiotherapy. (Meeting abstract). 1999 ASCO Annual Meeting. Abstract 279.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Stefoski Mikeljevic J, Haward R A, Johnston C, et al. Surgeon workload and survival from breast cancer. Br J Cancer. 2003;89(3):487-91. [pmid: 12888817].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Strom E A. Breast IMRT: New tools leading to new vision. Int J Radiat Oncol Biol Phys. 2002;54(5):1297-8. [pmid: 12459348].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Struikmans H, van Tienhoven G, Jobsen J J, et al. [Locoregional radiotherapy after mastectomy and chemotherapy for breast cancer: prolonged survival and better local tumor control]. [Dutch]. Ned Tijdschr Geneeskd. 1999;143(2):71-3. [pmid: 10086106].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Susman E. NCCN drops mention of high-dose chemotherapy from breast cancer treatment guidelines. Oncology Times. 2001;23(5):34.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Sweep C G, Geurts-Moespot J. EORTC external quality assurance program for ER and PgR measurements: trial 1998/1999. European Organisation for Research and Treatment of Cancer. Int J Biol Markers. 2000;15(1):62-9. [pmid: 10883894].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Swinbanks D. Korea leaps before it looks over gene therapy guidelines. Nature. 1997;387(6628):6. [pmid: 9384362].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Tafra L, McMasters K, Whitworth P, et al. Credentialing issues with sentinel lymph node staging for breast cancer. Am J Surg. 2000;180(4):268-73. [pmid: 11113433].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Takahashi K, Nishimura S, Tada K, et al. Indications and limits of breast conserving treatment. [Review] [20 refs] [Japanese]. Gan To Kagaku Ryoho. 2002;29(7):1125-31. [pmid: 12145991].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Tamaki Y, Miyoshi Y, Noguchi S. Adjuvant hormonal therapy. [Review] [17 refs]. Breast Cancer Res Treat. 2002;9(3):185-9. [pmid: 12353826].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Tardivon A A, Guinebretiere J M, Dromain C, et al. Imaging and management of nonpalpable lesions of the breast. [Review] [72 refs]. Eur J Radiol. 2002;42(1):2-9. [pmid: 12039019].
Not breast cancer diagnosis or treatment.
Tashiro H. Standard chemotherapy for metastatic breast cancer. [Review] [45 refs] [Japanese]. Nippon Rinsho. 2000;58(Suppl):246-53. [pmid: 11068442].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
The BRIDGE, Study Group. Responses of primary health care professionals to UK national guidelines on the management and referral of women with breast conditions. J Eval Clin Pract. 2002;8(3):319-25. [pmid: 12164978].
Not breast cancer in women.
Theriault R L. Fitting new modalities into practice guidelines. Acta Radiol Oncol. 1997;11(11A):145-9.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Thompson B L, O'Connor P, Boyle R, et al. Measuring clinical performance: comparison and validity of telephone survey and administrative data. Health Serv Res. 2001;36(4):813-25. [pmid: 11508641]. [pmcid: 1089258].
Not breast cancer in women.
Thuerlimann B. International consensus meeting on the treatment of primary breast cancer 2001, St. Gallen, Switzerland. Breast Cancer Res Treat 2001;8(4):294–7.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Tjalma W, Colpaert C, Schrijvers D, et al. Guidelines for the treatment of in situ ductal carcinoma of the breast. Tijdschr Geneeskd. 1999;55(19):1360-6.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Trillet-Lenoir V, Freyer G. [Advantage of using tumor markers in colorectal and breast cancers. Guidelines of the American Society of Clinical Oncology (ASCO)]. [French]. Bull Cancer. 1997;84(7):767-8. [pmid: 9339206].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Troeng T. [Surgical quality indicators in practice--some experiences]. [Swedish]. Lakartidningen. 2002;99(14):1612-4. [pmid: 12469582].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Tubiana M, Holland R, Kopans D B, et al. Commission of the European Communities “Europe Against Cancer” Programme. European School of Oncology Advisory Report. Management of non-palpable and small lesions found in mass breast screening. [Review] [70 refs]. Eur J Cancer. 1994;30A(4):538-47. [pmid: 8018417].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Turner M J. Local impact of the NHMRC early breast cancer guidelines. [comment]. Med J Aust. 1998;168(10):525. [pmid: 9631684].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Umemura S, Sakamoto G, Sasano H, et al. Evaluation of HER2 status: for the treatment of metastatic breast cancers by humanized anti-HER2 Monoclonal antibody (trastuzumab) (Pathological committee for optimal use of trastuzumab). [Review] [38 refs]. Breast Cancer Res Treat. 2001;8(4):316-20.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Urban N. Developing measures of mammography performance. Med Care. 2002;40(6 Suppl):III86-8. [pmid: 12064762].
Not breast cancer diagnosis or treatment.
USPSTF. Postmenopausal hormone replacement therapy for the primary prevention of chronic condition. Recommendations and rationale. U.S. Preventive Services Task Force. Am Fam Physician. 2003;67(2):358-64. [pmid: 12562158].
Not breast cancer in women.
Vacher-Lavenu M C. Quality control in histology-cytology. Breast cancer. Arch Anat Cytol Pathol. 1995;43(12):101-16. [pmid: 8526564].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Vaidya J S, Baum M, Haffty B G. Management of early-onset breast cancer and BRCA1 or BRCA2 status [1] (multiple letters). Lancet. 2002;360(9333):640-1. [pmid: 12241952].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Valdagni R, Italia C, Montanaro P, et al. Quality assurance in early breast cancer treatment: clinical aspects of postoperative, external, whole breast irradiation. [Review] [64 refs]. Recent Results Cancer Res. 1996;140:251-61. [pmid: 8787067].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Vamvakas E C. Perioperative blood transfusion and cancer recurrence: meta-analysis for explanation. Transfusion. 1995;35(9):760-8. [pmid: 7570938].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Van de Steene J, Soete G, Storme G. Adjuvant radiotherapy for breast cancer significantly improves overall survival: the missing link. Radiother Oncol. 2000;55(3):263-72. [pmid: 10869741].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
van Diest P J, Rahusen F D, Torrenga H, et al. [Summary of the guideline ‘Sentinel Lymph Node Biopsy for Breast Cancer’]. [Dutch]. Ned Tijdschr Geneeskd. 2001;145(1):53-4. [pmid: 11198969].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
van Enckevort P J, TenVergert E M, Schrantee S, et al. Economic evaluations of systemic adjuvant breast cancer treatments: methodological issues and a critical review. Crit Rev Oncol Hematol. 1999;32(2):113-24. [pmid: 10612011].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
van Leeuwen D. Developing a prioritization matrix for improving breast care--a complex project. J Healthc Qual. 2002;24(2):42-4. [pmid: 11942159].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
van Tienhoven G, Tuut M K, Nortier J W R, et al. Dutch Institute for Healthcare Improvement guideline ‘treatment of breast cancer’: Important document, but an open attitude to new evidence is necessary [1]. Ned Tijdschr Geneeskd. 2003;147(8):362-3. [pmid: 12661123].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Vandenberg T A, Bramwell V H, Levine M. Caution with breast-conserving surgery [1] (multiple letters). CMAJ. 2002;167(10):1099. [pmid: 12427689].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Vastag B. Consensus panel recommendations for treatment of early breast cancer. JAMA. 2000;284(21):2707-8. [pmid: 11135755].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Venables K, Winfield E, Deighton A, et al. A survey of radiotherapy quality control practice in the United Kingdom for the START trial. Radiother Oncol. 2001;60(3):311-8. [pmid: 11514011].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Vennin P. [Standards, Options and Recommendations (SOR) on hormone therapy in nonmetastatic cancer of the breast]]. [French]. Bull Cancer. 2000;87(12):948-50. [pmid: 11174127].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Vennin P, Taieb S, Carpentier P. [About standard: from rule to patient. Breast cancer as an example]. [French]. Bull Cancer. 2001;88(2):221-2. [pmid: 11371373].
Not breast cancer diagnosis or treatment.
Verkooijen H M, Fioretta G, De Wolf C, et al. Management of women with ductal carcinoma in situ of the breast: a population-based study. Ann Oncol. 2002;13(8):1236-45. [pmid: 12181247].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Vernon S W, Heckel V, Jackson G L. Medical outcomes of care for breast cancer among health maintenance organization and fee-for-service patients. Clin Cancer Res. 1995;1(2):179-84. [pmid: 9815971].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Veronesi U, Salvadori B, Luini A, et al. Breast conservation is a safe method in patients with small cancer of the breast. Long-term results of three randomised trials on 1,973 patients. Eur J Cancer. 1995;31A(10):1574-9. [pmid: 7488404].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Viehweg P, Heywang-Kohbrunner S H. MRI enhancement: Contrast products and the breast tissue specificity. Stud Mitt Gesch Benediktinerorden. 1996;6(2):94-6.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Viehweg P, Paprosch I, Strassinopoulou M, et al. Contrast-enhanced magnetic resonance imaging of the breast: interpretation guidelines. [Review] [50 refs]. Top Magn Reson Imaging. 1998;9(1):17-43. [pmid: 9617900].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Vinh-Hung V, Burzykowski T, Van de Steene J, et al. Post-surgery radiation in early breast cancer: survival analysis of registry data. Radiother Oncol. 2002;64(3):281-90. [pmid: 12242116].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Von Eschenbach A C. NCI remains committed to current mammography guidelines. Oncologist. 2002;7(3):170-1. [pmid: 12065784].
Not breast cancer diagnosis or treatment.
Von Minckwitz G. [There are now evidence-based guidelines for breast carcinoma. There are evidence-based guidelines for breast carcinoma. Individual therapy out? (interview by Dr. Judith Neumaier)]. [German]. MMW Fortschr Med. 2002;144(23):10. [pmid: 12119895].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Von Minckwitz G, Kaufmann M. Primary and adjuvant systematic therapy in operable breast cancer. Onkologe. 2002;8(8):847-52.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Von Minckwitz G, Brunnert K, Costa S D, et al. [Evidence-based recommendations on primary treatment of carcinomas of the breast]. [Review] [72 refs] [German]. Zentralbl Gynakol. 2002;124(5):293-303. [pmid: 12232814].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Von Minckwitz G, Costa S D, Brunnert K, et al. [Evidence-based recommendations on treating locoregional and distant metastases of carcinomas of the breast]. [Review] [54 refs] [German]. Zentralbl Gynakol. 2002;124(5):284-92. [pmid: 12232814].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
von Smitten K. What is the impact of guidelines for the surgical treatment of breast cancer?. Ann Chir Gynaecol. 1998;87(1):6-7. [pmid: 9598222].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Voogd A C, Louwman W J, Coebergh J W W, et al. New guidelines for adjuvant systemic treatment in breast cancer: Consequences at a hospital level. Ned Tijdschr Geneeskd. 2000;144(33):1572-4. [pmid: 10965364].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Voogd A C, Louwman W J, Coebergh J W, et al. [Impact of the new guidelines for adjuvant systemic treatment of breast cancer at hospital level]. [Dutch]. Ned Tijdschr Geneeskd. 2000;144(33):1572-4. [pmid: 10965364].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Voogd A C, van Beek M W, Crommelin M A, et al. Management of early breast cancer in southeast Netherlands since 1984. A population-based study. Regional Breast Cancer Study Group. Acta Oncol (Madr). 1994;33(7):753-7.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Wadman M. Panel softens cancer gene test warning. Nature. 1996;380(6575):573. [pmid: 11644770].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Wagner S K. Quality does not ensure breast center profitability. Diagn Imaging (San Franc). 1998;20(5):29-6. [pmid: 10180990].
Not breast cancer in women.
Walley D R, Augustine E, Saslow D, et al. American Cancer Society Lymphedema Workshop. Workgroup IV: Lymphedema treatment resources--professional education and availability of patient services. Cancer. 1998;83(12 Suppl American):2886-7. [pmid: 9874418].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Ward J E, Rissel C, Slaytor E. “Best practice” in surgical management of breast cancer.[comment]. Med J Aust. 1997;168(3):141. [pmid: 9397050].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Warsi A A, White S, McCulloch P M. Completeness of data entry in three cancer surgery database. Eur J Surg Oncol. 2002;28(8):850-6. [pmid: 12477477].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Watanabe T. Treatment of metastatic breast cancer patients: what is the standard care of the patients?. Jpn J Clin Oncol. 1998;28(6):355-6. [pmid: 9861231].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Weeks J C. Outcomes assessment in the NCCN. Oncology. 1997;11(11A):137-40. [pmid: 9430183].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial.
Weeks J C. A guide for the guideline reader.[comment]. Breast Cancer Res Treat. 1997;43(3):277-8. [pmid: 9150906].
Not breast cancer in women
Welch H G, Mogielnicki J. Presumed benefit: lessons from the American experience with marrow transplantation for breast cancer.[comment]. BMJ. 2002;324(7345):1088-92. [pmid: 11991918]. [pmcid: 1123033].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Wenzel C, Schmidinger M, Huber H. [Is there progress in chemotherapy for breast cancer?]. [Review] [115 refs] [German]. Wien Klin Wochenschr. 2001;113(9):306-20. [pmid: 11388076].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Weston A, Godbold J H. Polymorphisms of H-ras-1 and p53 in breast cancer and lung cancer: a meta-analysis. Environ Health Perspect. 1997;105(Suppl 4):919-26. [pmid: 9255581]. [pmcid: 1470041].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Whelan T, Marcellus D, Clark R, et al. Adjuvant radiotherapy for early breast cancer: patterns of practice in Ontario. CMAJ. 1993;149(9):1273-7. [pmid: 8221482]. [pmcid: 1485719].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Wickramanayake P D, Katay I, Josting A, et al. Systemic adjuvant therapy for breast cancer. Med Klin. 1996;91(10):646-53. [pmid: 9019642].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Wilson E, Feakins R. The use of a standard proforma in breast cancer reporting.[comment]. J Clin Pathol. 2002;55(9):719. [pmid: 12195010].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Winchester D. Surgeons and interventional radiologists: doing what's best for the patient. J Am Coll Surg. 1998;186(5):570-3. [pmid: 9583698].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Winchester D P, Cox J D. Standards for diagnosis and management of invasive breast carcinoma. American College of Radiology. American College of Surgeons. College of American Pathologists. Society of Surgical Oncology. [Review] [138 refs]. CA Cancer J Clin. 1998;48(2):83-107. [pmid: 9522824].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Wobbes T h. The Dutch College of General Practitioners' practice guideline ‘diagnosis of breast cancer’; reaction from the field of surgery. Ned Tijdschr Geneeskd. 2003;147(12):535-7. [pmid: 12693079].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Wolf E. Change in the first-line therapy of breast cancer is emerging. Pharmazeutische Zeitung. 1999;144(39):41.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Yarbro J W, Page D L, Fielding L P, et al. American Joint Committee on Cancer prognostic factors consensus conference.[comment]. [Review] [38 refs]. Cancer. 1999;86(11):2436-46. [pmid: 10590388].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Yaziji H, Gown A M. Controversies and guidelines in tissue-based HER-2/neu testing in breast cancer. MLO Med Lab Obs. 2002;34(6):12-6. [pmid: 12090214].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Yong WS, Khin LW, Samuel. Timing of breast surgery in premenopausal breast cancer patients. Cochrane Database Syst Rev. 2003;1, 2003.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Young W W, Marks S M, Kohler S A, et al. Dissemination of clinical results. Mastectomy versus lumpectomy and radiation therapy. Med Care. 1996;34(10):1003-17. [pmid: 8843927].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Zagame L, Mignot L. Adjuvant chemotherapy of breast cancer. Rev Prat. 2002;16(576):829-31.
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Zander A R, Kroger N. High-dosage treatment of breast cancer - In favour. Dtsch Med Wochenschr. 2001;126(39):1091. [pmid: 11602918].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Zarbo R J. The oncologic pathology report. Quality by design. Arch Pathol Lab Med. 2000;124(7):1004-10. [pmid: 10888776].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Zellars R, Wolff A C. Local failure and prognostic factors in ductal carcinoma in situ: concentration on recent publications. [Review] [15 refs]. Curr Opin Obstet Gynecol. 2003;15(1):9-12. [pmid: 12544496].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial
Zujewski J A. “Build quality in”--HER2 testing in the real world.[comment]. J Natl Cancer Inst. 2002;94(11):788-9. [pmid: 12048261].
Not a quality measure/ment, clinical practice guideline, systematic review or commentary/editorial

## Listing of Studies Excluded at Level 3

Aaltonen M, Kuopio T, Laine J, et al. Interpretation guidelines of DNA histograms from tissue sections of breast cancer. Anticancer Res. 2000;20(1B):547-51. [pmid: 10769723].
Not a quality measure/ment (Clinical Practice Guideline).
Abrams J S. Adjuvant therapy for breast cancer--results from the USA consensus conference. [Review] [40 refs]. Breast Cancer. 2001;8(4):298-304. [pmid: 11791121].
Not a quality measure/ment (Commentary/Editorial).
Adjuvant systemic therapy for women with node-positive breast cancer. The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. [Review][87 refs]. CMAJ 1998;158 Suppl 3:S52–64.
Not a quality measure/ment (Clinical Practice Guideline).
Adjuvant systemic therapy for women with node-negative breast cancer. The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. [Review][68 refs]. CMAJ 1998;158 Suppl 3:S43–51.
Not a quality measure/ment (Clinical Practice Guideline).
Adjuvant therapy for breast cancer. [Review][88 refs]. NIH Consensus Statement 2000;17(4):1–35.
Not a quality measure/ment (Systematic review).
Asch SM, Kerr EA, Hamilton EG, et al. Quality of care for oncologic conditions and HIV: a review of the literature and quality indicators. Santa Monica, CA: RAND, 2000.
Not a quality measure/ment (Systematic review).
ASCO special article. 1997 update of recommendations for the use of tumor markers in breast and colorectal cancer. J Clin Oncol 1998;16(2):793–5.
Not a quality measure/ment (Clinical Practice Guideline).
Axillary dissection. The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. Canadian Association of Radiation Oncologists. CMAJ 1998;158 Suppl 3:S22–6.
Not a quality measure/ment (Clinical Practice Guideline).
Balaton A L, Coindre J M, Collin F, et al. [Recommendations for the immunohistochemical evaluation of hormone receptors on paraffin sections of breast cancer. Study Group on Hormone Receptors using Immunohistochemistry FNCLCC/AFAQAP. National Federation of Centres to Combat Cancer/French Association for Quality Assurance in Pathology]. [French]. Ann Pathol. 1996;16(2):144-8. [pmid: 8767687].
Not a quality measure/ment (Clinical Practice Guideline).
Bast RC, Jr., Ravdin P, Hayes DF et-al. 2000 update of recommendations for the use of tumor markers in breast and colorectal cancer: clinical practice guidelines of the American Society of Clinical Oncology.[erratum appears in J Clin Oncol 2001 Nov 1;19(21):4185–8]. J Clin Oncol 2001;19(6):1865–78.
Not a quality measure/ment (Clinical Practice Guideline).
Basuyau J P, Blanc-Vincent M P, Bidart J M, et al. [Standards, Options and Recommendations (SOR) for tumor markers in breast cancer. SOR Working Group]. [French]. Bull Cancer. 2000;87(10):723-37. [pmid: 11084536].
Not a quality measure/ment (Clinical Practice Guideline).
Bataille N, Franc B. [Extemporaneous anatomo-pathological examinations in breast and thyroid diseases. Work Group assembled by the National Agency for Health Accreditation and Evaluation (ANAES)]. [Review] [225 refs] [French]. Ann Otolaryngol Chir Cervicofac. 1998;115(Suppl 1):S46-74. [pmid: 9827194].
Not a quality measure/ment (Clinical Practice Guideline).
Bergh J, Jonsson P E, Glimelius B, et al. A systematic overview of chemotherapy effects in breast cancer. [Review] [273 refs]. Acta Oncol. 2001;40(23):253-81. [pmid: 11441936].
Not a quality measure/ment (Systematic review).
Blamey R W. The British Association of Surgical Oncology Guidelines for surgeons in the management of symptomatic breast disease in the UK (1998 revision). BASO Breast Specialty Group. Eur J Surg Oncol. 1998;24(6):464-76. [pmid: 9870719].
Not a quality measure/ment (Clinical Practice Guideline).
Blamey R W. EUSOMA. Guidelines on endocrine therapy of breast cancer EUSOMA. Eur J Cancer. 2002;38(5):615-34. [pmid: 12008199].
Not a quality measure/ment (Clinical Practice Guideline).
Blichert-Toft M, Smola M G, Cataliotti L, et al. Principles and guidelines for surgeons--management of symptomatic breast cancer. On behalf of the European Society of Surgical Oncology.[comment]. Ann Chir Gynaecol. 1998;87(1):101-9. [pmid: 9598249].
Not a quality measure/ment (Clinical Practice Guideline).
Bloomfield D J. Should bisphosphonates be part of the standard therapy of patients with multiple myeloma or bone metastases from other cancers? An evidence-based review.[comment]. [Review] [42 refs]. J Clin Oncol. 1998;16(3):1218-25. [pmid: 9626231].
Not a quality measure/ment (Systematic review).
Bontenbal M, Nortier J W R, Beex L V A M, et al. [Adjuvant systemic therapy for patients with resectable breast cancer: guideline from the Dutch National Breast Cancer Platform and the Dutch Society for Medical Oncology]. [Dutch]. Ned Tijdschr Geneeskd. 2000;144(21):984-9. [pmid: 10858788].
Not a quality measure/ment (Clinical Practice Guideline).
Bottomley A, Therasse P. Quality of life in patients undergoing systemic therapy for advanced breast cancer. [Review] [40 refs]. Lancet Oncol. 2002;3(10):620-8. [pmid: 12372724].
Not a quality measure/ment (Systematic review).
Boyages J, Delaney G, Taylor R. Predictors of local recurrence after treatment of ductal carcinoma in situ: a meta-analysis. Cancer. 1999;85(3):616-28. [pmid: 10091735].
Not a quality measure/ment (Systematic review).
[Breast cancer. Text of recommendations. National Association of Accreditation and Health Evaluation]. [French]. J Radiol. 2000;81(3):269-80. [pmid: 10740079].
Not a quality measure/ment (Clinical Practice Guideline).
Breast cancer in women. Edinburgh, Scotland: SIGN, 1998 p; 62 p.
Not a quality measure/ment (Clinical Practice Guideline).
Breast radiotherapy after breast-conserving surgery. The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. Canadian Association of Radiation Oncologists. [Review][67 refs]. CMAJ 1998;158 Suppl 3:S35–42.
Not a quality measure/ment (Clinical Practice Guideline).
British Association of Surgical Oncology Guidelines. The management of metastatic bone disease in the United Kingdom. The Breast Specialty Group of the British Association of Surgical Oncology. [Review][62 refs]. Eur J Surg Oncol 1999;25(1):3–23.
Not a quality measure/ment (Clinical Practice Guideline).
Burke W, Daly M, Garber J, et al. Recommendations for follow-up care of individuals with an inherited predisposition to cancer. II. BRCA1 and BRCA2. Cancer Genetics Studies Consortium.[comment]. [Review] [120 refs]. JAMA. 1997;277(12):997-1003. [pmid: 9091675].
Not a quality measure/ment (Clinical Practice Guideline).
Cantin J, Scarth H, Levine M, et-al. Clinical practice guidelines for the care and treatment of breast cancer: 13. Sentinel lymph node biopsy.[comment][erratum appears in CMAJ 2001 Sep 18;165(6):744]. CMAJ 2001;165(2):166–73.
Not a quality measure/ment (Commentary/Editorial).
Carlson R W, Goldstein L J, Gradishar W J, et al. NCCN Breast Cancer Practice Guidelines. The National Comprehensive Cancer Network. Oncology (Huntington). 1996;10(11 Suppl):47-75.
Not a quality measure/ment (Clinical Practice Guideline).
Carlson R W, Anderson B O, Bensinger W, et al. NCCN Practice Guidelines for Breast Cancer. Oncology (Huntington). 2000;14(11A):33-49.
Not a quality measure/ment (Clinical Practice Guideline).
Chlebowski R T, Aiello E, McTiernan A. Weight loss in breast cancer patient management. [Review] [158 refs]. J Clin Oncol. 2002;20(4):1128-43. [pmid: 11844838].
Not a quality measure/ment (Systematic review).
Clahsen P C, Van De Velde C J, Goldhirsch A, et al. Overview of randomized perioperative polychemotherapy trials in women with early-stage breast cancer. J Clin Oncol. 1997;15(7):2526-35. [pmid: 9215821].
Not a quality measure/ment (Systematic review).
Clinical practice guidelines for the use of tumor markers in breast and colorectal cancer. Adopted on May 17, 1996 by the American Society of Clinical Oncology. J Clin Oncol 1996;14(10):2843–77.
Not a quality measure/ment (Clinical Practice Guideline).
Clinical practice guidelines for the care and treatment of breast cancer: a Canadian consensus document. CMAJ. 1998;158(3):Suppl-S83.
Not a quality measure/ment (Clinical Practice Guideline).
Col N F, Hirota L K, Orr R K, et al. Hormone replacement therapy after breast cancer: a systematic review and quantitative assessment of risk. [Review] [62 refs]. J Clin Oncol. 2001;19(8):2357-63. [pmid: 11304788].
Not a quality measure/ment (Systematic review).
Collins J P, Simpson J S. Guidelines for the surgical management of breast cancer. Council of the Royal Australasian College of Surgeons.[comment]. Aust N Z J Surg. 1998;68(Suppl):1-28. [pmid: 9566171].
Not a quality measure/ment (Clinical Practice Guideline).
Concin H, Grunberger W, Kubista E, et al. [Guidelines for treatment of breast carcinoma by the Gynecological Oncology Working Group. Gynecological Oncology Working Group]. [German]. Gynakol Geburtshilfliche Rundsch. 1999;39(4):226-9. [pmid: 10629389].
Not a quality measure/ment (Clinical Practice Guideline).
Consortium's early results show collaborative guidelines work. Qual Lett Healthc Lead. 1999;11(4):11–2.
Not a quality measure/ment (Commentary/Editorial).
Crump M, Sawka C A, DeBoer G, et al. An individual patient-based meta-analysis of tamoxifen versus ovarian ablation as first line endocrine therapy for premenopausal women with metastatic breast cancer. Breast Cancer Res Treat. 1997;44(3):201-10. [pmid: 9266099].
Not a quality measure/ment (Systematic review).
Deming S L, Nass S J, Dickson R B, et al. C-myc amplification in breast cancer: a meta-analysis of its occurrence and prognostic relevance. Br J Cancer. 2000;83(12):1688-95. [pmid: 11104567].
Not a quality measure/ment (Systematic review).
de Bock G H, Beusmans G H M I, Hinloopen R, et al. The guidelines of the Dutch College of General Practitioners on diagnosis of breast carcinoma. Huisarts Wet. 2002;45(9):466-72.
Not a quality measure/ment (Clinical Practice Guideline).
Diagnosis and management of specific breast abnormalities. Evidence Report: Technology Assessment (Summary). 2001;(33):1–4.
Not a quality measure/ment (Systematic review).
Dolan J T, Miltenburg D M, Granchi T S, et al. Treatment of metastatic breast cancer with somatostatin analogues--a meta-analysis. Ann Surg Oncol. 2001;8(3):227-33. [pmid: 11314939].
Not a quality measure/ment (Systematic review).
Dose J, Kotzerke J, Schicha H, et al. Clinical value of FDG PET in the diagnosis of gynecological tumors: Recommendations of the 3rd interdisciplinary German consensus conference ‘PET in Oncology III’. Geburtshilfe Frauenheilkd. 2002;62(7):644-51.
Not a quality measure/ment (Systematic review).
Early Breast Cancer Trialists' Collaborative Group. Radiotherapy for early breast cancer. [Review][65 refs]. Cochrane Database Syst Rev 2002;(2):CD003647.
Not a quality measure/ment (Systematic review).
Early Breast Cancer Trialists' Collaborative Group. Multi-agent chemotherapy for early breast cancer. [Review][83 refs]. Cochrane Database Syst Rev 2002;(1):CD000487.
Not a quality measure/ment (Systematic review).
Early Breast Cancer Trialists' Collaborative Group. Tamoxifen for early breast cancer. [Review][31 refs]. Cochrane Database Syst Rev 2001;(1):CD000486.
Not a quality measure/ment (Systematic review).
Early Breast Cancer Trialists' Collaborative Group. Ovarian ablation for early breast cancer.[update of Cochrane Database Syst Rev. 2000;(2):CD000485; PMID: 10796722]. [Review][19 refs]. Cochrane Database Syst Rev. 2000;(3):CD000485.
Not a quality measure/ment (Systematic review).
Edelman M J, Meyers F J, Siegel D. The utility of follow-up testing after curative cancer therapy. A critical review and economic analysis. [Review] [133 refs]. J Gen Intern Med. 1997;12(5):318-31. [pmid: 9159703]. [pmcid: 1497113].
Not a quality measure/ment (Systematic review).
Effects of radiotherapy and surgery in early breast cancer. An overview of the randomized trials. Early Breast Cancer Trialists' Collaborative Group.[comment][erratum appears in N Engl J Med 1996 Apr 11;334(15):1003]. N Engl J Med 1995;333(22):1444–1455.
Not a quality measure/ment (Systematic review).
Eifel P, Axelson J A, Costa J, et al. National Institutes of Health Consensus Development Conference Statement: adjuvant therapy for breast cancer, November 1–3, 2000. [Review] [97 refs]. J Natl Cancer Inst. 2001;93(13):979-89. [pmid: 11438563].
Not a quality measure/ment (Commentary/Editorial).
Eisinger F, Alby N, Bremond A, et al. Recommendations for medical management of hereditary breast and ovarian cancer: the French National Ad Hoc Committee. Ann Oncol. 1998;9(9):939-950. [pmid: 9818066].
Not a quality measure/ment (Clinical Practice Guideline).
Eisinger F, Alby N, Bremond A, et al. [INSERM-FNCLCC collective expert's report. Recommendations for management of women having a genetic risk of developing breast and/or ovarian cancer. National Federation of Centers of the Fight Against Cancer]. [French]. Ann Endocrinol (Paris). 1998;59(6):470-84. [pmid: 10189990].
Not a quality measure/ment (Clinical Practice Guideline).
Emery C, Gallagher R, Hugi M, et al. Clinical practice guidelines for the care and treatment of breast cancer: the management of chronic pain in patients with breast cancer (summary of the 2001 update). CMAJ. 2001;165(9):1218-9. [pmid: 11706911]. [pmcid: 81584].
Not a quality measure/ment (Commentary/Editorial).
Erickson V S, Pearson M L, Ganz P A, et al. Arm edema in breast cancer patients. [Review] [115 refs]. J Natl Cancer Inst. 2001;93(2):96-111. [pmid: 11208879].
Not a quality measure/ment (Systematic review).
Farquhar C, Basser R, Hetrick S, et al. High dose chemotherapy and autologous bone marrow or stem cell transplantation versus conventional chemotherapy for women with metastatic breast cancer. [Review][43 refs]. Cochrane Database Syst Rev 2003;(1):CD003142.
Not a quality measure/ment (Systematic review).
Farquhar C, Basser R, Marjoribanks J, et al. High dose chemotherapy and autologous bone marrow or stem cell transplantation versus conventional chemotherapy for women with early poor prognosis breast cancer. [Review] Cochrane Database Syst Rev. 2003;(1):CD003139. [43 refs].
Not a quality measure/ment (Systematic review).
Favourable and unfavourable effects on long-term survival of radiotherapy for early breast cancer: an overview of the randomised trials. Early Breast Cancer Trialists' Collaborative Group. Lancet 2000;355(9217):1757–70.
Not a quality measure/ment (Systematic review).
Ferrandina G, Scambia G, Bardelli F, et al. Relationship between cathepsin-D content and disease-free survival in node-negative breast cancer patients: a meta-analysis. Br J Cancer. 1997;76(5):661-6. [pmid: 9303368].
Not a quality measure/ment (Systematic review).
Findlay B P, Walker-Dilks C. Epirubicin, alone or in combination chemotherapy, for metastatic breast cancer. Provincial Breast Cancer Disease Site Group and the Provincial Systemic Treatment Disease Site Group. Cancer Prev Control. 1998;2(3):140-6. [pmid: 10093625].
Not a quality measure/ment (Clinical Practice Guideline).
Fish E B. Guideline for managing breast lumps.[comment]. Can J Surg. 1999;42(2):150-1. [pmid: 10223081].
Not a quality measure/ment (Clinical Practice Guideline).
Fizazi K, Zelek L. Is one cycle every three or four weeks' obsolete? A critical review of dose-dense chemotherapy in solid neoplasms. [Review] [139 refs]. Ann Oncol. 2000;11(2):133-49. [pmid: 10761747].
Not a quality measure/ment (Systematic review).
Flobbe K, Nelemans P J, Kessels A G, et al. The role of ultrasonography as an adjunct to mammography in the detection of breast cancer. a systematic review. [Review] [72 refs]. Eur J Cancer. 2002;38(8):1044-50. [pmid: 12008191].
Not a quality measure/ment (Systematic review).
Fodor J, Polgar C, Nemeth G. [Evidence-based radiotherapy in the treatment of operable breast cancer: results in the 1990-ies]. [Review] [40 refs] [Hungarian]. Orv Hetil. 2000;141(28):1551-5. [pmid: 10957865].
Not a quality measure/ment (Systematic review).
Follow-up after treatment for breast cancer. The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. [Review][56 refs]. CMAJ 1998;158 Suppl 3:S65–70.
Not a quality measure/ment (Clinical Practice Guideline).
Fonseca R, Hartmann L C, Petersen I A, et al. Ductal carcinoma in situ of the breast. [Review] [98 refs]. Ann Intern Med. 1997;127(11):1013-22. [pmid: 9412283].
Not a quality measure/ment (Systematic review).
Fossati R, Confalonieri C, Torri V, et al. Cytotoxic and hormonal treatment for metastatic breast cancer: a systematic review of published randomized trials involving 31,510 women. [Review] [213 refs]. J Clin Oncol. 1998;16(10):3439-60. [pmid: 9779724].
Not a quality measure/ment (Systematic review).
Fourquet A, Cutuli B, Luporsi E, et al. [“Standards, Options and Recommendations 2001” for radiotherapy in patients with non-metastatic infiltrating breast cancer. Update. National Federation of Cancer Campaign Centers (FNCLCC)]. [French]. Cancer Radiother. 2002;6(4):238-58. [pmid: 12224489].
Not a quality measure/ment (Clinical Practice Guideline).
Funke I, Schraut W. Meta-analyses of studies on bone marrow micrometastases: an independent prognostic impact remains to be substantiated. J Clin Oncol. 1998;16(2):557-66. [pmid: 9469341].
Not a quality measure/ment (Systematic review).
Gale R P, Park R E, Dubois R, et al. Delphi-panel analysis of appropriateness of high-dose chemotherapy and blood cell or bone marrow autotransplants in women with breast cancer. Clin Transplant. 2000;14(1):32-41. [pmid: 10693633].
Not a quality measure/ment (Systematic review).
Ghersi D, Wilcken N, Simes J, et al. Taxane containing regimens for metastatic breast cancer. Cochrane Database Syst Rev 2003;(3):CD003366.
Not a quality measure/ment (Systematic review).
Glimelius B, Bergh J, Brandt L, et al. The Swedish Council on Technology Assessment in Health Care (SBU) systematic overview of chemotherapy effects in some major tumour types--summary and conclusions. [Review] [17 refs]. Acta Oncol. 2001;40(23):135-54. [pmid: 11441927].
Not a quality measure/ment (Systematic review).
Goldhirsch A, Glick J H, Gelber R D, et al. International Consensus Panel on the treatment of primary breast cancer. V: Update 1998. [Review] [44 refs]. Recent Results Cancer Res. 1998;152:481-97. [pmid: 9928582].
Not a quality measure/ment (Clinical Practice Guideline).
Goldhirsch A, Glick J H, Gelber R D, et al. Meeting highlights: International Consensus Panel on the Treatment of Primary Breast Cancer. Seventh International Conference on Adjuvant Therapy of Primary Breast Cancer. [Review] [84 refs]. J Clin Oncol. 2001;19(18):3817-27. [pmid: 11559719].
Not a quality measure/ment (Commentary/Editorial).
Goodwin P J, Black J T, Bordeleau L J, et al. Health-related quality-of-life measurement in randomized clinical trials in breast cancer--taking stock. [Review] [93 refs]. J Natl Cancer Inst. 2003;95(4):263-81. [pmid: 12591983].
Not a quality measure/ment (Systematic review).
Gotay C C, Muraoka M Y. Quality of life in long-term survivors of adult-onset cancers. [Review] [100 refs]. J Natl Cancer Inst. 1998;90(9):656-67. [pmid: 9586662].
Not a quality measure/ment (Systematic review).
Guidelines M. [Guideline for clarification of the palpable breast finding]. [German]. Gynakol Geburtshilfliche Rundsch. 2001;41(3):189-96. [pmid: 11904475].
Not a quality measure/ment (Clinical Practice Guideline).
Guidelines for cytology procedures and reporting on fine needle aspirates of the breast. Cytology Subgroup of the National Coordinating Committee for Breast Cancer Screening Pathology. Cytopathology 1994;5(5):316–34.
Not a quality measure/ment (Clinical Practice Guideline).
Haffty B G. Who's on first? Sequencing chemotherapy and radiation therapy in conservatively managed node-negative breast cancer.[comment]. [Review] [16 refs]. Cancer J Sci Am. 1999;5(3):147-9. [pmid: 10606475].
Not a quality measure/ment (Commentary/Editorial).
Harris S R, Hugi M R, Olivotto I A, et al. Clinical practice guidelines for the care and treatment of breast cancer: 11. Lymphedema. CMAJ. 2001;164(2):191-9. [pmid: 11332311]. [pmcid: 80678].
Not a quality measure/ment (Clinical Practice Guideline).
Harris S R, Hugi M R, Olivotto I A, et al. Upper extremity rehabilitation in women with breast cancer after axillary dissection: clinical practice guidelines. Critical Reviews in Physical & Rehabilitation Medicine. 2001;13(23):91-103.
Not a quality measure/ment (Clinical Practice Guideline).
Hartman A R, Fleming G F, Dillon J J. Meta-analysis of adjuvant cyclophosphamide/methotrexate/5-fluorouracil chemotherapy in postmenopausal women with estrogen receptor-positive, node-positive breast cancer. Clin Breast Cancer. 2001;2(2):138-43. [pmid: 11899785].
Not a quality measure/ment (Systematic review).
Health care guideline: breast cancer diagnosis. In: Institute for Clinical Systems Integration 1996, Volume 1 Bloomington, MN:ICSI-22.
Not a quality measure/ment (Clinical Practice Guideline).
Hebert-Croteau N, Freeman C R, Latreille J, et al. Delay in adjuvant radiation treatment and outcomes of breast cancer--a review. [Review] [43 refs]. Breast Cancer Res Treat. 2002;74(1):77-94. [pmid: 12150455].
Not a quality measure/ment (Systematic review).
Heisey R, Mahoney L, Watson B. Management of palpable breast lumps. Consensus guideline for family physicians.[comment]. [Review] [26 refs]. Can Fam Physician. 1999;45:1926-32. [pmid: 10463093].
Not a quality measure/ment (Clinical Practice Guideline).
Helewa M, Levesque P, Provencher D, et al. Breast cancer, pregnancy, and breastfeeding. J Obstet Gynaecol Can: JOGC. 2002;24(2):164-80.
Not a quality measure/ment (Clinical Practice Guideline).
Hensley M L, Schuchter L M, Lindley C, et al. American Society of Clinical Oncology clinical practice guidelines for the use of chemotherapy and radiotherapy protectants. J Clin Oncol. 1999;17(10):3333-55. [pmid: 10506637].
Not a quality measure/ment (Clinical Practice Guideline).
Hillner B E, Ingle J N, Berenson J R, et al. American Society of Clinical Oncology guideline on the role of bisphosphonates in breast cancer. American Society of Clinical Oncology Bisphosphonates Expert Panel. J Clin Oncol. 2000;18(6):1378-91. [pmid: 10715310].
Not a quality measure/ment (Clinical Practice Guideline).
Hortobagyi G N. Developments in chemotherapy of breast cancer. [Review] [96 refs]. Cancer. 2000;88(12 Suppl):3073-9. [pmid: 11147589].
Not a quality measure/ment (Commentary/Editorial).
Hoshaw S J, Klein P J, Clark B D, et al. Breast implants and cancer: causation, delayed detection, and survival. Plast Reconstr Surg. 2001;107(6):1393-1407. [pmid: 11335807].
Not a quality measure/ment (Systematic review).
Hrung J M, Sonnad S S, Schwartz J S, et al. Accuracy of MR imaging in the work-up of suspicious breast lesions: a diagnostic meta-analysis. Acad Radiol. 1999;6(7):387-97. [pmid: 10410164].
Not a quality measure/ment (Systematic review).
Huang J, Barbera L, Brouwers M, et-al. Does delay in starting treatment affect the outcomes of radiotherapy? A systematic review.[erratum appears in J Clin Oncol. 2003 Apr 1;21(7):1424]. J Clin Oncol 2003:21(3):555–63.
Not a quality measure/ment (Systematic review).
ICSI health care guideline: breast cancer detection. In: Institute for Clinical Systems Integration 1993/1994 health care guidelines Bloomington, MN:ICSI-45.
Not a quality measure/ment (Clinical Practice Guideline).
Investigation of lesions detected by mammography. The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. Canadian Association of Radiation Oncologists.[comment]. CMAJ 1998;158 Suppl 3:9–14.
Not a quality measure/ment (Clinical Practice Guideline).
Irwig L, Bennetts A. Quality of life after breast conservation or mastectomy: a systematic review.[comment]. Aust N Z J Surg. 1997;67(11):750-4. [pmid: 9396988].
Not a quality measure/ment (Clinical Practice Guideline).
Johnson P W, Simnett S J, Sweetenham J W, et al. Bone marrow and peripheral blood stem cell transplantation for malignancy. [Review] [209 refs]. Health Technol Assess. 1998;2(8):1-187. [pmid: 9728295].
Not a quality measure/ment (Systematic review).
Kasumi F, Yoshimoto M, Uchino J, et al. Meta-analysis of five studies on tegafur plus uracil (UFT) as post-operative adjuvant chemotherapy for breast cancer. Oncology. 2003;64(2):146-53. [pmid: 12566912].
Not a quality measure/ment (Systematic review).
Kattlove H, Liberati A, Keeler E, et al. Benefits and costs of screening and treatment for early breast cancer. Development of a basic benefit package.[comment]. JAMA. 1995;273(2):142-8. [pmid: 7799495].
Not a quality measure/ment (Systematic review).
Keshtgar M R, Ell P J. Clinical role of sentinel-lymph-node biopsy in breast cancer. [Review] [32 refs]. Lancet Oncol. 2002;3(2):105-10. [pmid: 11905458].
Not a quality measure/ment (Systematic review).
Klijn J G, Blamey R W, Boccardo F, et al. Combined tamoxifen and luteinizing hormone-releasing hormone (LHRH) agonist versus LHRH agonist alone in premenopausal advanced breast cancer: a meta-analysis of four randomized trials. J Clin Oncol. 2001;19(2):343-53. [pmid: 11208825].
Not a quality measure/ment (Systematic review).
Kotwall C A. Breast cancer treatment and chemoprevention. [Review] [23 refs]. Can Fam Physician. 1999;45:1917-24. [pmid: 10463092].
Not a quality measure/ment (Systematic review).
Kubista E. [Diagnosis and therapy of breast cancer]. [German]. Wien Klin Wochenschr. 1999;111(16):655-9. [pmid: 10510844].
Not a quality measure/ment (Clinical Practice Guideline).
Kurtz J. EUSOMA Working Party. The curative role of radiotherapy in the treatment of operable breast cancer. Eur J Cancer. 2002;38(15):1961-74. [pmid: 12376199].
Not a quality measure/ment (Clinical Practice Guideline).
Langlands A. Implementing clinical practice guidelines.[comment]. Med J Aust. 2000;173(3):164-5. [pmid: 10979387].
Not a quality measure/ment (Commentary/Editorial).
Leibel S A. ACR appropriateness criteria. Expert Panel on Radiation Oncology. American College of Radiology.[comment]. [Review] [190 refs]. Int J Radiat Oncol Biol Phys. 1999;43(1):125-68. [pmid: 10524412].
Not a quality measure/ment (Clinical Practice Guideline).
Levine M. Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. Clinical practice guidelines for the care and treatment of breast cancer: adjuvant systemic therapy for node-positive breast cancer (summary of the 2001 update). The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer.[comment]. CMAJ. 2001;164(5):644-6. [pmid: 11706911]. [pmcid: 80819].
Not a quality measure/ment (Clinical Practice Guideline).
Levine M. Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. Clinical practice guidelines for the care and treatment of breast cancer: adjuvant systemic therapy for node-negative breast cancer (summary of the 2001 update).[erratum appears in CMAJ 2001 Feb 20;164(4):465]. CMAJ. 2001;164(2):213. [pmid: 11706911]. [pmcid: 80684].
Not a quality measure/ment (Clinical Practice Guideline).
Lewis R, Bagnall A M, King S, et al. The clinical effectiveness and cost-effectiveness of vinorelbine for breast cancer: a systematic review and economic evaluation. [Review] [415 refs]. Health Technol Assess. 2002;6(14):1-269. [pmid: 12583816].
Not a quality measure/ment (Systematic review).
Lewis R, Bagnall A M, Forbes C, et al. The clinical effectiveness of trastuzumab for breast cancer: a systematic review. [Review] [82 refs]. Health Technol Assess. 2002;6(13):1-71. [pmid: 12583816].
Not a quality measure/ment (Systematic review).
Liljegren G. Is postoperative radiotherapy after breast conserving surgery always mandatory? A review of randomised controlled trials. [Review] [15 refs]. Scand J Surg. 2002;91(3):251-4. [pmid: 12449467].
Not a quality measure/ment (Systematic review).
Lister-Sharp D, McDonagh M S, Khan K S, et al. A rapid and systematic review of the effectiveness and cost-effectiveness of the taxanes used in the treatment of advanced breast and ovarian cancer. [Review] [87 refs]. Health Technol Assess. 2000;4(17):1-113. [pmid: 11074389].
Not a quality measure/ment (Systematic review).
Malin J L, Asch S M, Kerr E A, et al. Evaluating the quality of cancer care: development of cancer quality indicators for a global quality assessment tool. Cancer. 2000;88(3):701-7. [pmid: 10649266].
Not a quality measure/ment (Systematic review).
Mastectomy or lumpectomy? The choice of operation for clinical stages I and II breast cancer. The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. Canadian Association of Radiation Oncologists.[comment]. CMAJ. 1998;158 Suppl 3:S15–21.
Not a quality measure/ment (Clinical Practice Guideline).
Mauriac L, Blanc-Vincent M P, Luporsi E, et al. [Standards, Options and Recommendations (SOR) for endocrine therapy in patients with non metastatic breast cancer. FNCLCC]. [Review] [147 refs] [French]. Bull Cancer. 2000;87(6):469-90. [pmid: 10903789].
Not a quality measure/ment (Clinical Practice Guideline).
Mauriac L. [Standards, Options and Recommendations for non metastatic breast cancer patients]. [French]. Bull Cancer. 2002;89(2):207-24. [pmid: 11888860].
Not a quality measure/ment (Clinical Practice Guideline).
McDermott E W. Irish guidelines for surgeons in the management of breast cancer. Irish Society of Surgical Oncology. Ir Med J. 1910;90(1):6-8. [pmid: 9230549].
Not a quality measure/ment (Clinical Practice Guideline).
Megens A, Harris S R. Physical therapist management of lymphedema following treatment for breast cancer: a critical review of its effectiveness. [Review] [39 refs]. Phys Ther. 1998;78(12):1302-11. [pmid: 9859949].
Not a quality measure/ment (Systematic review).
Meiser B, Halliday J L. What is the impact of genetic counselling in women at increased risk of developing hereditary breast cancer? A meta-analytic review. Soc Sci Med. 2002;54(10):1463-70. [pmid: 12061481].
Not a quality measure/ment (Systematic review).
Messori A, Cattel F, Trippoli S, et al. Survival in patients with metastatic breast cancer: analysis of randomized studies comparing oral aromatase inhibitors versus megestrol. Anticancer Drugs. 2000;11(9):701-6. [pmid: 11129731].
Not a quality measure/ment (Systematic review).
Meurer L N, Lena S. Cancer recurrence and mortality in women using hormone replacement therapy: meta-analysis. J Fam Pract. 2002;51(12):1056-62. [pmid: 12540332].
Not a quality measure/ment (Systematic review).
Miltenburg D M, Miller C, Karamlou T B, et al. Meta-analysis of sentinel lymph node biopsy in breast cancer. J Surg Res. 1999;84(2):138-42. [pmid: 10357910].
Not a quality measure/ment (Systematic review).
Mirza A N, Mirza N Q, Vlastos G, et al. Prognostic factors in node-negative breast cancer: a review of studies with sample size more than 200 and follow-up more than 5 years. [Review] [88 refs]. Ann Surg. 2002;235(1):10-26. [pmid: 11753038]. [pmcid: 1422391].
Not a quality measure/ment (Systematic review).
Mirsky D, O'Brien SE, McCready DR, et-al. Surgical management of early stage invasive breast cancer (stage I and II). Provincial Breast Disease Site Group.[erratum appears in Cancer Prev Control 1997 Jun;1(2):132]. Cancer Prev Control 1997;1(1):10–7.
Not a quality measure/ment (Clinical Practice Guideline).
Mlika-Cabanne N, Bellet D. [Serum markers for breast and colorectal cancers. Working group reunited by the National Health Agency for Accreditation and Evaluation (NHAAE)]. [Review] [167 refs] [French]. Gastroenterol Clin Biol. 1998;22(4):442-57. [pmid: 9762275].
Not a quality measure/ment (Clinical Practice Guideline).
Moller P, Evans G, Haites N, et al. Guidelines for follow-up of women at high risk for inherited breast cancer: consensus statement from the Biomed 2 Demonstration Programme on Inherited Breast Cancer. [Review] [24 refs]. Dis Markers. 1999;15(13):207-11. [pmid: 10595280].
Not a quality measure/ment (Clinical Practice Guideline).
Morris A D, Morris R D, Wilson J F, et al. Breast-conserving therapy vs mastectomy in early-stage breast cancer: a meta-analysis of 10-year survival. Cancer J Sci Am. 1997;3(1):6-12. [pmid: 9072310].
Not a quality measure/ment (Systematic review).
Morrow M, Bland KI, Foster R. Breast cancer surgical practice guidelines. Society of Surgical Oncology practice guidelines. Oncology (Huntington) 885;11(6):877–81.
Not a quality measure/ment (Clinical Practice Guideline).
Morrow M, Strom E A, Bassett L W, et al. Standard for the management of ductal carcinoma in situ of the breast (DCIS). [Review] [120 refs]. CA Cancer J Clin. 2002;52(5):256-76. [pmid: 12363326].
Not a quality measure/ment (Clinical Practice Guideline).
Morrow M, Strom E A, Bassett L W, et al. Standard for breast conservation therapy in the management of invasive breast carcinoma.[comment]. [Review] [100 refs]. CA Cancer J Clin. 2002;52(5):277-300. [pmid: 12363326].
Not a quality measure/ment (Clinical Practice Guideline).
Mourits M J, de Vries E G, Willemse P H, et al. Tamoxifen treatment and gynecologic side effects: a review. [Review] [124 refs]. Obstet Gynecol. 2001;97(5 Pt 2):855-66. [pmid: 11336777].
Not a quality measure/ment (Systematic review).
Myers R E, Johnston M, Pritchard K, et al. Baseline staging tests in primary breast cancer: a practice guideline. CMAJ. 2001;164(10):1439-44. [pmid: 11387916]. [pmcid: 81070].
Not a quality measure/ment (Clinical Practice Guideline).
Neuhauser D, Evans J T. Assessment of surgical operations for ductal carcinoma in situ of the breast. Int J Technol Assess Health Care. 1997;13(3):420-9. [pmid: 9308272].
Not a quality measure/ment (Systematic review).
Newman L A, Mason J, Cote D, et al. African-American ethnicity, socioeconomic status, and breast cancer survival: a meta-analysis of 14 studies involving over 10,000 African-American and 40,000 White American patients with carcinoma of the breast. Cancer. 2002;94(11):2844-54. [pmid: 12115371].
Not a quality measure/ment (Systematic review).
NHS Centre for Reviews and Dissemination. Primary systemic therapy in operable breast cancer (Structured abstract). Database of Abstracts of Reviews of Effectiveness (DARE). 2003;Issue 1, 2003.
Not a quality measure/ment (Systematic review).
NHS Centre for Reviews and Dissemination. Physical therapist management of lymphedema following treatment for breast cancer. Database of Abstracts of Reviews of Effectiveness (DARE). 2003;Issue 1, 2003.
Not a quality measure/ment (Systematic review).
NHS Centre for Reviews and Dissemination. Quality of life after breast conservation or mastectomy. Database of Abstracts of Reviews of Effectiveness (DARE). 2003;Issue 1, 2003.
Not a quality measure/ment (Systematic review).
NHS Centre for Reviews and Dissemination. Should bisphosphonates be part of the standard therapy of patients with multiple myeloma or bone metastases from other cancers. Database of Abstracts of Reviews of Effectiveness (DARE). 2003;Issue 1, 2003.
Not a quality measure/ment (Systematic review).
NHS Centre for Reviews and Dissemination. Combined chemo-endocrine adjuvant therapy for patients with operable breast cancer. Database of Abstracts of Reviews of Effectiveness. 2003;Issue 1, 2003.
Not a quality measure/ment (Systematic review).
NHS Centre for Reviews and Dissemination. Cytotoxic and hormonal treatment for metastatic breast cancer. Database of Abstracts of Reviews of Effectiveness. 2003;Issue 1, 2003.
Not a quality measure/ment (Systematic review).
NHS Centre for Reviews and Dissemination. A rapid and systematic review of the effectiveness and cost-effectiveness of the taxanes used in the treatment of advanced breast and ovarian cancer (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2003;Issue 1, 2003.
Not a quality measure/ment (Systematic review).
NHS Centre for Reviews and Dissemination. Accuracy of MR imaging in the work-up of suspicious breast lesions. Database of Abstracts of Reviews of Effectiveness. 2003;Issue 1, 2003.
Not a quality measure/ment (Systematic review).
NHS Centre for Reviews and Dissemination. Exercise as rehabilitation for cancer patients (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2003; Issue 1, 2003.
Not a quality measure/ment (Systematic review).
NHS Centre for Reviews and Dissemination. Epirubicin, alone or in combination chemotherapy, for metastatic breast cancer (Structured abstract). Database of Abstracts of Reviews of Effectiveness. 2003; Issue 1, 2003.
Not a quality measure/ment (Systematic review).
Noguchi M. Does regional treatment improve the survival in patients with operable breast cancer?. Breast Cancer Res Treat. 2002;76(3):269-82. [pmid: 12462388].
Not a quality measure/ment (Systematic review).
O'Higgins N, Linos D A, Blichert-Toft M, et al. European guidelines for quality assurance in the surgical management of mammographically detected lesions. European Breast Cancer Working Group. Ann Chir Gynaecol. 1998;87(1):110-2. [pmid: 9598249].
Not a quality measure/ment (Clinical Practice Guideline).
Olivotto I, Levine M. Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. Clinical practice guidelines for the care and treatment of breast cancer: the management of ductal carcinoma in situ (summary of the 2001 update). [Review] [8 refs]. CMAJ. 2001;165(7):912-3. [pmid: 11599333]. [pmcid: 81502].
Not a quality measure/ment (Commentary/Editorial).
Orr R K. The impact of prophylactic axillary node dissection on breast cancer survival--a Bayesian meta-analysis.[comment]. Ann Surg Oncol. 1999;6(1):109-16. [pmid: 10030423].
Not a quality measure/ment (Systematic review).
Ovarian ablation for early breast cancer. Early Breast Cancer Trialists' Collaborative Group.[update in Cochrane Database Syst Rev. 2000;(3):CD000485]. [Review][12 refs]. Cochrane Database Syst Rev. 2000;(2):CD000485.
Not a quality measure/ment (Systematic review).
Ovarian ablation in early breast cancer: overview of the randomised trials. Early Breast Cancer Trialists' Collaborative Group. Lancet 1996;348(9036):1189–96.
Not a quality measure/ment (Systematic review).
Owen J. 1996 decision trees and management guidelines. Semin Radiat Oncol. 1997;7(2):163-81. [pmid: 10717210].
Not a quality measure/ment (Clinical Practice Guideline).
Pain S J, Purushotham A D. Lymphoedema following surgery for breast cancer. [Review] [145 refs]. Br J Surg. 2000;87(9):1128-41. [pmid: 10971418].
Not a quality measure/ment (Systematic review).
Partial consensus about breast and cancer treatment in Florence. [Review]. Ann Oncol 1998;9(12):1257.
Not a quality measure/ment (Clinical Practice Guideline).
Pavlakis N, Stockler M. Bisphosphonates for breast cancer. [Review][39 refs]. Cochrane Database Syst Rev 2002;(1):CD003474.
Not a quality measure/ment (Systematic review).
Pharoah P D, Day N E, Caldas C. Somatic mutations in the p53 gene and prognosis in breast cancer: a meta-analysis. Br J Cancer. 1999;80(12):1968-73. [pmid: 10471047].
Not a quality measure/ment (Systematic review).
Piccart M, Cataliotti L, Buchanan M, et al. Brussels Statement document. [Review] [6 refs]. Eur J Cancer. 2001;37(11):1335-7. [pmid: 11435061].
Not a quality measure/ment (Commentary/Editorial).
Piccart M J. Proposed treatment guidelines for HER2-positive metastatic breast cancer in Europe. [Review] [52 refs]. Ann Oncol. 2001;12(Suppl 1):S89-94. [pmid: 11843245].
Not a quality measure/ment (Commentary/Editorial).
Pierce LJ. Treatment guidelines and techniques in delivery of postmastectomy radiotherapy in management of operable breast cancer J Natl Cancer Inst Monogr 2001;(30):117–24.
Not a quality measure/ment (Commentary/Editorial).
Polychemotherapy for early breast cancer: an overview of the randomised trials. Early Breast Cancer Trialists' Collaborative Group.[comment]. Lancet 1998;352(9132):930–42.
Not a quality measure/ment (Systematic review).
Pritchard K I, Khan H, Levine M, et al. Clinical practice guidelines for the care and treatment of breast cancer: 14. The role of hormone replacement therapy in women with a previous diagnosis of breast cancer. [Review] [46 refs]. CMAJ. 2002;166(8):1017-22. [pmid: 12002977]. [pmcid: 100875].
Not a quality measure/ment (Clinical Practice Guideline).
Proudhom M A, Noel G, Mazeron J J. [Tamoxifen and early-stage breast cancer: meta-analysis of randomized trials]. [French]. Cancer Radiother. 1999;3(4):341. [pmid: 10630168].
Not a quality measure/ment (Systematic review).
Questions and answers on breast cancer. A guide for women and their physicians. Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. CMAJ 1998;158(3 Suppl):1–31.
Not a quality measure/ment (Clinical Practice Guideline).
Ramirez A J, Westcombe A M, Burgess C C, et al. Factors predicting delayed presentation of symptomatic breast cancer: a systematic review.[comment]. [Review] [34 refs]. Lancet. 1999;353(9159):1127-31. [pmid: 10209975].
Not a quality measure/ment (Systematic review).
Rauschecker H, Clarke M, Gatzemeier W, et al. Systemic therapy for treating locoregional recurrence in women with breast cancer. [Review][18 refs]. Cochrane Database Syst Rev 2001;(4):CD002195.
Not a quality measure/ment (Systematic review).
Recommendations for the reporting of breast carcinoma. Association of Directors of Anatomic and Surgical Pathology. Hum Pathol 1996;27(3):220–4.
Not a quality measure/ment (Clinical Practice Guideline).
Recommended breast cancer surveillance guidelines. American Society of Clinical Oncology. J Clin Oncol 1997;15(5):2149–56.
Not a quality measure/ment (Clinical Practice Guideline).
[Recommendations for the immunohistochemistry of the hormonal receptors on paraffin sections in breast cancer. Update 1999. Group for Evaluation of Prognostic Factors using Immunohistochemistry in Breast Cancer (GEFPICS-FNCLCC)].[erratum appears in Ann Pathol 1999 Dec;19(6):486]. [French]. Ann Pathol 1999;19(4):336–43.
Not a quality measure/ment (Clinical Practice Guideline).
Reske SN, Kotzerke J. FDG-PET for clinical use. Results of the 3rd German Interdisciplinary Consensus Conference, “Onko-PET III”, 21 July and 19 September 2000. [Review][182 refs]. Eur J Nucl Med 2001;28(11):1707–23.
Not a quality measure/ment (Systematic review).
Richards M A, Westcombe A M, Love S B, et al. Influence of delay on survival in patients with breast cancer: a systematic review.[comment]. [Review] [103 refs]. Lancet. 1999;353(9159):1119-26. [pmid: 10209974].
Not a quality measure/ment (Systematic review).
Rietman J S, Dijkstra P U, Hoekstra H J, et al. Late morbidity after treatment of breast cancer in relation to daily activities and quality of life: A systematic review 33. Eur J Surg Oncol. 2003;29(3):229-38. [pmid: 12657232].
Not a quality measure/ment (Systematic review).
Rintasyoparyhma ry S. [Recommended treatment guideline for breast cancer. Finnish Breast Cancer Group]. [Finnish]. Duodecim. 1997;113(22):2341-8. [pmid: 10892143].
Not a quality measure/ment (Clinical Practice Guideline).
Robert G, Milne R. Positron emission tomography: establishing priorities for health technology assessment. [Review] [39 refs]. Health Technol Assess. 1999;3(16):1-54. [pmid: 10632626].
Not a quality measure/ment (Systematic review).
Rock CL, Demark-Wahnefried W. Nutrition and survival after the diagnosis of breast cancer: a review of the evidence. [erratum appears in J Clin Oncol 2002 Sep 15;20(18):3939]. [Review][117 refs]. J Clin Oncol 2002;20(15):3302–16.
Not a quality measure/ment (Systematic review).
Rogers M, Kristjanson L J. The impact on sexual functioning of chemotherapy-induced menopause in women with breast cancer. [Review] [92 refs]. Cancer Nurs. 2002;25(1):57-65. [pmid: 11838721].
Not a quality measure/ment (Systematic review).
Rojas MP, Telaro E, Russo A, et al. Follow-up strategies for women treated for early breast cancer. [Review][22 refs]. Cochrane Database Syst Rev 2000;(4):CD001768.
Not a quality measure/ment (Systematic review).
Rutgers E J, Nortier J W, Tuut M K, et al. [Dutch Institute for Healthcare Improvement guideline, “Treatment of breast cancer”].[comment]. [Dutch]. Ned Tijdschr Geneeskd. 2002;146(45):2144-51. [pmid: 12474555].
Not a quality measure/ment (Clinical Practice Guideline).
Rutgers E J. EUSOMA Consensus Group. Quality control in the locoregional treatment of breast cancer. Eur J Cancer. 2001;37(4):447-53. [pmid: 11267852].
Not a quality measure/ment (Clinical Practice Guideline).
Sainsbury R. Towards appropriate local surgery for patients with breast cancer.[comment]. Lancet. 2000;356(9236):1124-5. [pmid: 11030285].
Not a quality measure/ment (Commentary/Editorial).
Samson D J, Flamm C R, Pisano E D, et al. Should FDG PET be used to decide whether a patient with an abnormal mammogram or breast finding at physical examination should undergo biopsy?. [Review] [30 refs]. Acad Radiol. 2002;9(7):773-83. [pmid: 12139091].
Not a quality measure/ment (Systematic review).
Sandrucci S, Casalegno P S, Percivale P, et al. Sentinel lymph node mapping and biopsy for breast cancer: a review of the literature relative to 4791 procedures. [Review] [98 refs]. Tumori. 1999;85(6):425-34. [pmid: 10774561].
Not a quality measure/ment (Systematic review).
Sautter-Bihl M L, Guttenberger R. [Meta-analysis confirms improved survival rate by locoregional radiotherapy of breast carcinoma]. [German]. Strahlenther Onkol. 2000;176(9):434-5. [pmid: 11050919].
Not a quality measure/ment (Systematic review).
Scarth H, Cantin J, Levine M, et al. Clinical practice guidelines for the care and treatment of breast cancer: mastectomy or lumpectomy? The choice of operation for clinical stages I and II breast cancer (summary of the 2002 update).[comment]. CMAJ. 2002;167(2):154-5. [pmid: 12160123]. [pmcid: 117094].
Not a quality measure/ment (Clinical Practice Guideline).
Schwartz GF, Guiliano AE, Veronesi U, et-al. Proceeding of the consensus conference of the role of sentinel lymph node biopsy in carcinoma or the breast April 19–22, 2001, Philadelphia, PA, USA. Breast J 2002;8(3):124–38.
Not a quality measure/ment (Clinical Practice Guideline).
Sevelda P. [Tamoxifen in the treatment of patients with breast cancer: results of the latest meta-analysis of prospective randomized clinical trials]. [German]. Gynakol Geburtshilfliche Rundsch. 1998;38(2):81-4. [pmid: 9815522].
Not a quality measure/ment (Systematic review).
Seymour L, Bramwell V, Moran L A. Use of dexrazoxane as a cardioprotectant in patients receiving doxorubicin or epirubicin chemotherapy for the treatment of cancer. The Provincial Systemic Treatment Disease Site Group. Cancer Prev Control. 1999;3(2):145-59. [pmid: 10474762].
Not a quality measure/ment (Clinical Practice Guideline).
Shell J A. Evidence-based practice for symptom management in adults with cancer: sexual dysfunction. [Review] [104 refs]. Oncol Nurs Forum. 2002;29(1):53-66. [pmid: 11817493].
Not a quality measure/ment (Systematic review).
Shimozuma K, Okamoto T, Katsumata N, et al. Systematic overview of quality of life studies for breast cancer. [Review] [11 refs]. Breast Cancer. 2002;9(3):196-202. [pmid: 12185329].
Not a quality measure/ment (Systematic review).
Silva O E, Zurrida S. Breast cancer: a guide for fellows. Crit Rev Oncol Hematol. 1999;29(12):1-207. [pmid: 10380716].
Not a quality measure/ment (Systematic review).
Simnett S J, Stewart L A, Sweetenham J, et al. Autologous stem cell transplantation for malignancy: a systematic review of the literature. [Review] [33 refs]. Clin Lab Haematol. 2000;22(2):61-72. [pmid: 10792394].
Not a quality measure/ment (Systematic review).
Sloane J P, Amendoeira I, Apostolikas N, et al. [Guidelines for pathology--supplement to European guidelines for quality assurance in mammography screening. Report by the Pathology Working Group of the European Community]. [German]. Pathologe. 1997;18(1):71-88. [pmid: 9157408].
Not a quality measure/ment (Clinical Practice Guideline).
Smith T J, Davidson N E, Schapira D V, et al. American Society of Clinical Oncology 1998 update of recommended breast cancer surveillance guidelines. J Clin Oncol. 1999;17(3):1080-2. [pmid: 10071303].
Not a quality measure/ment (Clinical Practice Guideline).
Sparano J A. Taxanes for breast cancer: an evidence-based review of randomized phase II and phase III trials. [Review] [26 refs]. Clin Breast Cancer. 2000;1(1):32-40. [pmid: 11899388].
Not a quality measure/ment (Systematic review).
Stockler M, Wilcken N R, Ghersi D, et al. Systematic reviews of chemotherapy and endocrine therapy in metastatic breast cancer. [Review] [79 refs]. Cancer Treat Rev. 2000;26(3):151-68. [pmid: 10814559].
Not a quality measure/ment (Systematic review).
Sturgeon C. Practice guidelines for tumor marker use in the clinic. [Review] [64 refs]. Clin Chem. 2002;48(8):1151-9. [pmid: 12142367].
Not a quality measure/ment (Systematic review).
Taguchi T. Meeting highlights--International Consensus Panel on the treatment of primary breast cancer. [Review] [84 refs]. Gan To Kagaku Ryoho. 2002;29(3):347-63. [pmid: 12484030].
Not a quality measure/ment (Clinical Practice Guideline).
Takashima S, Saeki T. Guidelines for proper use of antineoplastic agents. Breast cancer. [Japanese]. Gan to Kagaku Ryoho [Japanese Journal of Cancer & Chemotherapy]. 2002;29(6):1025-46.
Not a quality measure/ment (Clinical Practice Guideline).
Tamoxifen for early breast cancer: an overview of the randomised trials. Early Breast Cancer Trialists' Collaborative Group.[comment]. Lancet 1998;351(9114):1451–67.
Not a quality measure/ment (Systematic review).
Tang N L, Choy K W, Pang C P, et al. Prevalence of breast cancer predisposition gene mutations in Chinese women and guidelines for genetic testing. Clin Chim Acta. 2001;313(12):179-85. [pmid: 11694257].
Not a quality measure/ment (Commentary/Editorial).
Temple L K, Wang E E, McLeod R S. Preventive health care, 1999 update: 3. Follow-up after breast cancer. Canadian Task Force on Preventive Health Care. CMAJ. 1999;161(8):1001-8. [pmid: 10551200]. [pmcid: 1230673].
Not a quality measure/ment (Clinical Practice Guideline).
The management of primary breast cancer. [196 refs]. York: NHS Centre for Reviews and Dissemination, 1996 p; 16 p.
Not a quality measure/ment (Systematic review).
The management of ductal carcinoma in situ (DCIS). The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. Canadian Association of Radiation Oncologists.[comment]. [Review][74 refs]. CMAJ 1998;158 Suppl 3:S277ndash;34.
Not a quality measure/ment (Clinical Practice Guideline).
The management of chronic pain in patients with breast cancer. The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. Canadian Society of Palliative Care Physicians. Canadian Association of Radiation Oncologists.[comment]. [Review] [88 refs]. CMAJ. 1998;158(Suppl 3):S71-S81. [pmid: 9484281].
Not a quality measure/ment (Clinical Practice Guideline).
The National Institutes of Health Consensus Development Conference: Adjuvant Therapy for Breast Cancer. Bethesda, Maryland, USA. November 1–3, 2000. Proceedings. J Natl Cancer Inst. 2001; Monographs.(30):1–152.
Not a quality measure/ment (Clinical Practice Guideline).
The palpable breast lump: information and recommendations to assist decision-making when a breast lump is detected. The Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. Canadian Association of Radiation Oncologists. CMAJ 1998;158 Suppl 3:S3–8.
Not a quality measure/ment (Clinical Practice Guideline).
The Royal College of Radiologists' Clinical Oncology Information Network. Guidelines on the non-surgical management of breast cancer. Clin Oncol (R Coll Radiol). 1999;11(3):90-133. [pmid: 10465465].
Not a quality measure/ment (Clinical Practice Guideline).
The uniform approach to breast fine-needle aspiration biopsy. NIH Consensus Development Conference. [Review]. [91 refs]. Am J Surg 1997;174(4):371–85.
Not a quality measure/ment (Clinical Practice Guideline).
The uniform approach to breast fine-needle aspiration biopsy. National Cancer Institute Fine-Needle Aspiration of Breast Workshop Subcommittees. Diagn Cytopathol 1997;16(4):295–311.
Not a quality measure/ment (Clinical Practice Guideline).
Trock B J, Leonessa F, Clarke R. Multidrug resistance in breast cancer: a meta-analysis of MDR1/gp170 expression and its possible functional significance.[comment]. J Natl Cancer Inst. 1997;89(13):917-31. [pmid: 9214671].
Not a quality measure/ment (Systematic review).
Trock B, Leonessa F, Clarke R. Multidrug resistance in breast cancer: a meta-analysis of the occurrence and prognostic significance of MDR1/gp170 expression (Meeting abstract). Proc Am Assoc Cancer Res Annual Meeting. 1996;37.
Not a quality measure/ment (Systematic review).
Update of the NCCN guidelines for treatment of breast cancer. Oncology (Huntington). 1997;11(11A):199–220.
Not a quality measure/ment (Clinical Practice Guideline).
Update: NCCN practice guidelines for the treatment of breast cancer. National Comprehensive Cancer Network. Oncology (Huntington) 1999;13(5A):41–66.
Not a quality measure/ment (Clinical Practice Guideline).
Valero V, Hortobagyi G N. Are anthracycline-taxane regimens the new standard of care in the treatment of metastatic breast cancer?[comment]. J Clin Oncol. 2003;21(6):959-62. [pmid: 12972520].
Not a quality measure/ment (Commentary/Editorial).
Verkooijen H M, Peeters P H, Buskens E, et al. Diagnostic accuracy of large-core needle biopsy for nonpalpable breast disease: a meta-analysis. Br J Cancer. 2000;82(5):1017-21. [pmid: 10737383].
Not a quality measure/ment (Systematic review).
Vicini F A, Recht A. Age at diagnosis and outcome for women with ductal carcinoma-in-situ of the breast: a critical review of the literature. [Review] [62 refs]. J Clin Oncol. 2002;20(11):2736-44. [pmid: 12039936].
Not a quality measure/ment (Systematic review).
Watanabe T, Katsumata N, Saijo N. [Treatment guideline for advanced or recurrent breast cancer]. [Review] [26 refs] [Japanese]. Nippon Rinsho. 2000;58(Suppl):237-45. [pmid: 11026016].
Not a quality measure/ment (Clinical Practice Guideline).
Whelan T J, Julian J, Wright J, et al. Does locoregional radiation therapy improve survival in breast cancer? A meta-analysis. J Clin Oncol. 2000;18(6):1220-9. [pmid: 10715291].
Not a quality measure/ment (Systematic review).
Whelan T, Olivotto I, Levine M, et al. Clinical practice guidelines for the care and treatment of breast cancer: breast radiotherapy after breast-conserving surgery (summary of the 2003 update). CMAJ. 2003;168(4):437-9. [pmid: 12591786]. [pmcid: 143551].
Not a quality measure/ment (Clinical Practice Guideline).
Whelan T J, Lada B M, Laukkanen E, et al. Breast irradiation in women with early stage invasive breast cancer following breast conservation surgery. Provincial Breast Disease Site Group. Cancer Prev Control. 1997;1(3):228-40. [pmid: 9765748].
Not a quality measure/ment (Clinical Practice Guideline).
Wiersma T J, de Bock G H, Assendelft W J J. Summary of the Dutch College of General Practitioners' practice guideline ‘Diagnosis of breast cancer’ 47. Ned Tijdschr Geneeskd. 2003;147(12):547-50. [pmid: 12693083].
Not a quality measure/ment (Clinical Practice Guideline).
Williams C, Collingwood M, Simera I, et al. Short versus long duration infusions of paclitaxel for any adenocarcinoma. Cochrane Database Syst Rev 2003;(1):CD003911.
Not a quality measure/ment (Systematic review).
Winchester D P, Strom E A. Standards for diagnosis and management of ductal carcinoma in situ (DCIS) of the breast. American College of Radiology. American College of Surgeons. College of American Pathologists. Society of Surgical Oncology. [Review] [113 refs]. CA Cancer J Clin. 1998;48(2):108-28. [pmid: 9522825].
Not a quality measure/ment (Clinical Practice Guideline).
Winer E P, Hudis C, Burstein H J, et al. American Society of Clinical Oncology technology assessment on the use of aromatase inhibitors as adjuvant therapy for women with hormone receptor-positive breast cancer: status report 2002. J Clin Oncol. 2002;20(15):3317-27. [pmid: 12149306].
Not a quality measure/ment (Systematic review).
Wong R, Wiffen PJ. Bisphosphonates for the relief of pain secondary to bone metastases. Cochrane Database Syst Rev 2002;(2):CD002068.
Not a quality measure/ment (Systematic review).
Woodward V, Webb C. Women's anxieties surrounding breast disorders: a systematic review of the literature. J Adv Nurs. 2001;33(1):29-41. [pmid: 11155106].
Not a quality measure/ment (Systematic review).
Wright J R, Whelan T J, McCready D R, et al. Management of ductal carcinoma in situ of the breast. Provincial Breast Cancer Disease Site Group. Cancer Prev Control. 1998;2(6):312-9. [pmid: 10470463].
Not a quality measure/ment (Clinical Practice Guideline).
Wyld L, Reed M W. The need for targeted research into breast cancer in the elderly. [Review] [117 refs]. Br J Surg. 2003;90(4):388-99. [pmid: 12673739].
Not a quality measure/ment (Systematic review).
Yamada Y, Ackerman I, Franssen E, et al. Does the dose fractionation schedule influence local control of adjuvant radiotherapy for early stage breast cancer? [Review] [42 refs]. Int J Radiat Oncol Biol Phys. 1999;44(1):99-104. [pmid: 10219801].
Not a quality measure/ment (Systematic review).
Yamauchi H, Stearns V, Hayes D F. When is a tumor marker ready for prime time? A case study of c-erbB-2 as a predictive factor in breast cancer. [Review] [138 refs]. J Clin Oncol. 2001;19(8):2334-56. [pmid: 11304787].
Not a quality measure/ment (Systematic review)