# Figure

## Figure 1. Analytic framework regarding the measurement of the quality of breast cancer care

[image]