# Summary Tables

Summary Table 1. Preoperative diagnosis

Summary Table 1. Preoperative diagnosis

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/Key differences
Appropriate use: If a palpable breast mass has been detected, at least one of the following procedures should be completed within 3 months: fine-needle aspiration, mammography, ultrasound, biopsy, and/or a followup visit ^ IV ^
McGlynn, 2003, US | Random sample of women living in 12 US metropolitan areas | 77 | 1998-2000 | 89.1%/NA
Appropriate use of preoperative mammographic evaluation ^ IV ^
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994; ≤3 mo prior mass excision | 727 | 1995-1996 | 91.5%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 88%/Age: <70 y: 88.5%; ≥70 y: 86.2%/ Race/ethnicity: White: 88.4%; Black-H: 86.5%/Payer: Government: 87.7%; Private: 88.7%

KEY: Key differences = regarding age, race, ethnicity, or SES; SES = socioeconomic status; NA = not assessed; BC = breast cancer; NR = not reported; QOL = quality of life ; DCIS = ductal carcinoma in situ; S = significant difference; NS = nonsignificant difference; Mx = mammography; F = followup; b = baseline; HMO = Health Maintenance Organization; H = Hispanic; Level Ia = pre-study data indicating consistently sound psychometric properties; Iac = pre- and on-study data indicating consistently sound psychometric properties; IV = no pre- or on-study psychometric data

Summary Table 2. Preoperative diagnosis

Summary Table 2. Preoperative diagnosis

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/Key differences
Appropriate use of imaging &/or cytology or needle biopsy, if required, to be performed at the initial visit ^ IV ^
Cheung, 1999, Hong Kong | Convenience sample of women with operable primary BC <5 cm; attended by the author | 100 | NR | 0%/NA
Appropriate use of preoperative diagnosis by fine-needle aspiration cytology, needle histology or biopsy ^ IV ^
Sauven, 2003, UK | Population-based sample BC women detected by screening in UK, Wales, Scotland & Northern Ireland | 43,500 | 1996-2001 | NR (Overall by y (range): 63% – 87%(Minimum: ≥70%; Standard: ≥90%))/NA
Christensen, 2002, Denmark | Convenience sample women with positive mammography screening followed by surgery in Copenhagen | 4,111 | 1991-1997 | NA/100%
Cheung, 1999, Hong Kong | Convenience sample women operable primary BC <5 cm; attended by the author | 100 | NR | 82% (Standard: 90%)/NA
McCarthy, 1997, UK | Convenience sample women with operable BC, <70 y treated at Nottingham City Hospital's | 83 | 1994 | 86.7% (Standard: ≥70%)/NA
Appropriate use: A biopsy or fine-needle aspiration should be performed within 6 weeks either when the mammography suggests malignancy or the persistent palpable mass is not cystic on ultrasound ^ IV ^
McGlynn, 2003, US | Random sample of women living in 12 US metropolitan areas | 33 | 1998-2000 | 50.2%/NA
Appropriate use: If a breast mass has been detected on two separate occasions, then either a biopsy, fine-needle aspiration or ultrasound should be performed within 3 months of the second visit ^ IV ^
McGlynn, 2003, US | Random sample of women living in 12 US metropolitan areas | 13 | 1998-2000 | 81.6%/NA
Quality of fine-needle aspiration samples from lesions, which subsequently prove to be breast cancer, should be adequate as deemed by the breast pathologist ^ IV ^
Cheung, 1999, Hong Kong | Convenience sample women with operable primary BC < 5 cm; attended by the author | 100 | NR | 99% (Standard: >90%)/NA

Summary Table 3. Surgical procedures

Summary Table 3. Surgical procedures

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Appropriate use: A biopsy should be performed within 6 weeks if fine-needle aspiration cannot rule out malignancy ^ IV ^
McGlynn, 2003, US | Random sample of women living in 12 US metropolitan areas | 2 | 1998-2000 | 100%/NA
Appropriate use of first localization biopsy operation to correctly identify impalpable lesions ^ IV ^
McCarthy, 1997, UK | Convenience sample women operable BC, <70 y at Nottingham City Hospital's | 11 | 1994 | 100% (Standard: >95%)/NA
Quality of breast biopsy: primary operable breast cancer receives a frozen section ^ IV ^
Cheung, 1999, Hong Kong | Convenience sample women operable primary BC <5 cm; attended by the author | 100 | NR | 0% (Standard: <10%)/NA
Quality of technique to determine histological node status for all invasive tumors, either by sampling or clearance ^ IV ^
Sauven, 2003, UK | Population-based sample BC women detected by screening in UK, Wales, Scotland & Northern Ireland | 43,500 | 1996-2001 | NR (Overall by y (range): 81%–93%)/NA
Cheung, 1999, Hong Kong | Convenience sample women operable primary BC <5 cm; attended by the author | 100 | NR | 100%/NA
Quality of sampling nodes for invasive breast cancer, to include ≥ 4 nodes ^ IV ^
Sauven, 2003, UK | Population-based sample BC women detected by screening in UK, Wales, Scotland & Northern Ireland | 43,500 | 1996-2001 | NR (Overall by y (range): 89%– 95%)/NA
Quality of hormone receptor assay ^ IV ^
Bickell, 2000, US | Convenience sample women BC stage I–II, receiving definitive surgical treatment in 4 hospitals in NY | 723 | 1995-1996 | 85%/by hospital: 56–99 %

Summary Table 4. QOL and patient satisfaction relating to diagnosis

Summary Table 4. QOL and patient satisfaction relating to diagnosis

Author, year, Location | Sample description | No. Eligible | Measurement Period | Results
Change in QOL after diagnosis of breast cancer ^ Iac ^
Northouse, 1999, US | Convenience sample black women with a confirmed diagnosis of BC who were at least 1 mo post-diagnosis, Southeastern region in Michigan | 98 | NR | NR (Average: fairly high QOL scale/Variables: Node (+): lower QOL (Mean: 110.8) than node (-) (Mean: 120.7); Recurrence of cancer: lower QOL (Mean: 107.1) than not recurrence (Mean: 118.2))/NA
Women reporting an overall satisfaction with the quality of breast care ^ IV ^
Haas, 2000, US | Convenience sample women referred for at least 1 visit GP, 1 y prior to Mx; abnormal screening Mx or Mx for a clinical breast concern (lump, thickening, breast pain) in Greater Boston Area | 579 (baseline); 447 (followup survey) | 1996 -1997 | Excellent care: 46.8%(b) 45.8% (F)/Age: < 50 y: 44.4% (b); 46.6% (F); ≥ 50 y: 49.3% (b); 44.9% (F)/Race/ethnicity: White: 51.9% (b); 49.8% (F); Black: 35.9% (b); 35.6% (F); Hispanic: 33.3% (b); 25% (F)/Payer: HMO: 42.9% (b); 42.4% (F); Other: 52.8% (b); 50.7% (F)

Summary Table 5. General category

Summary Table 5. General category

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Appropriate use of referrals to surgeon by general practitioner according to breast referral guidelines ^ IV ^
Cochrane, 1997, UK | Random sample women >35 y breast problems referred to a surgeon by GP, Rapid Access Breast Clinic | 2,332 (BC = 147) | 1995 | 60%/Age: <40 y: 54%; >40 y: 64% S
>90% of women with breast cancer detected by screening should attend an assessment center within 3 weeks of mammography ^ IV ^
McCarthy, 1997, UK | Convenience sample women operable BC, <70 y at Nottingham City Hospital's | 75 | 1994 | 42.7%/NA
Patients attending for diagnostic purposes seen on at least 1 occasion by a breast specialist surgeon ^ IV ^
Cheung, 1999, Hong Kong | Convenience sample women operable primary BC <5 cm; attended by the author | 100 | NR | 100%/NA
<10% of all new cases of women with breast cancer should attend the clinic/hospital on > 2 occasions for diagnostic purposes ^ IV ^
Cheung, 1999, Hong Kong | Convenience sample women operable primary BC <5 cm; attended by the author | 100 | NR | 41%/NA
Urgent referrals of women with breast cancer to be seen within 5 working days ^ IV ^
Khawaja, 2001, UK | Convenience sample women BC referred by GP to specialist to diagnose: breast lump; suspicion of malignant change; other breast symptoms in Eastbourne | 22 | 3 mo (1998) | 82% (Standard: > 80%)/Age: 41–65 y: 27.3%; >65 y: 54.5%
Cheung, 1999, Hong Kong | Convenience sample women operable primary BC <5 cm; attended by the author | 100 | NR | 95% (Standard: >80%)/NA
Women with breast cancer to be seen by specialist in timely fashion post referral for diagnostic purposes ^ IV ^
Khawaja, 2001, UK | Convenience sample women BC referred by GP to specialist to diagnose: breast lump; suspicion of malignant change; other breast symptoms in Eastbourne | 22 | 3 mo (1998) | 100% (Standard: ≥80%)/Age: >65 y: 18.2%
Cheung, 1999, Hong Kong | Convenience sample women operable primary BC < 5 cm; attended by the author | 100 | NR | 50% (Standard: 70%)/NA

Summary Table 6. General category

Summary Table 6. General category

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/Key differences
Management of cases coming to surgery from the screening program carried out by surgeons who have acquired the necessary specialist knowledge ^ IV ^
Sauven, 2003, UK | Population-based sample BC women detected by screening in UK, Wales, Scotland & Northern Ireland | 43,500 | 1996-2001 | NR (Overall by y & case load range): > 30pts/y, high*: 63%–72%; < 10 pts/y, low: 5%– 8%)/NA
≥90% of women requiring an operation for diagnostic purposes should be admitted within 14 days of the surgical decision ^ IV ^
Sauven, 2003, UK | Population-based sample BC women detected by screening in UK, Wales, Scotland & Northern Ireland | 2,979 | 1996-2001 | NR (Overall by y (range): 52%– 60%)/NA
Cheung, 1999, Hong Kong | Convenience sample women operable primary BC <5 cm; attended by the author | 100 | NR | 68%/NA
McCarthy, 1997, UK | Convenience sample women operable BC, <70 y treated at Nottingham City Hospital's | 11 | 1994 | 45.5%/NA
≥90% of women with breast cancer or with an abnormality requiring diagnostic operation need to be told of this within 5 working days of investigations leading to this diagnosis ^ IV ^
Cheung, 1999, Hong Kong | Convenience sample women operable primary BC < 5 cm; attended by the author | 100 | NR | 67%/NA
Appropriate use of an evaluation in compliance with guidelines ^ IV ^
Haas, 2000, US | Convenience sample women referred for at least 1 visit GP, 1 y prior to Mx; abnormal screening Mx or Mx for a clinical breast concern (lump, thickening, breast pain) in Greater Boston Area | 579 | 1996-1997 | 69.1%/Age: <50 y: 63.8%; >50: 74.5 %/ Race/ ethnicity: White: 71%; Black: 59.5%; Hispanic: 75.8%/Payer: HMO: 73.3%; other: 62%
Appropriate use of initial examination ^ IV ^
Ray-Coquard, 1997, France | Random sample women with newly diagnosed localized BC (DCIS to nonmetastatic invasive carcinoma) in a cancer center in Rhone Alpes Area | 71 | 1995 | 86%/NA

Summary Table 7. Surgery

Summary Table 7. Surgery

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use: Women with stage I or stage II breast cancer should be offered a choice of modified radical mastectomy or breast-conserving surgery, unless contraindications to breast-conserving surgery are present ^ IV ^
McGlynn, 2003, US | Random sample of women living in 12 US metropolitan areas | 13 | 1998-2000 | 50.2%/NA
Appropriate use of all surgery ^ IV ^
Ray-Coquard, 1997, France | Random sample women with localized BC (DCIS to nonmetastatic invasive carcinoma) in a cancer center in Rhone Alpes Area | 99 | 1995 | 92%/NA
No breast-conserving surgery or mastectomy in metastatic disease ^ IV ^
Hislop, 2003, Canada | Population-based sample women any stage BC diagnosed in British Columbia | NR (Total = 1,159) | 1995 | 65%/NA

KEY: Key differences = regarding age, race, ethnicity, or SES; SES = socioeconomic status; NA = not assessed; CT = chemotherapy; RT = radiotherapy, BC = breast cancer; BCS = breast-conserving surgery; HT = hormone therapy; NR = not reported; ESBC = early stage breast cancer; QOL = quality of life; Dx = diagnosis; DCIS = ductal carcinoma in situ; S = significant difference; NS = nonsignificant difference; QLI = quality of life index; LCIS = lobular carcinoma in situ; CME = continuing medical education; ALND = axillary lymph node dissection; LN = lymph node; (+) = positive; (-) = negative; ER = estrogen receptor; HR = hormone receptor; RI = Rhode Island; MA = Massachusetts; MN = Minnesota; CMF = cyclophosphamide, methotrexate, 5-fluorouracil; M0 = nonmetastatic; Level Ia = pre-study data indicating consistently sound psychometric properties; Iac = pre- and on-study data indicating consistently sound psychometric properties; IV = no pre- or on-study psychometric data

Summary Table 8. Surgery

Summary Table 8. Surgery

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of breast-conserving surgery ^ IV ^
Mandelblatt, 2001, US | National random sample, Medicare beneficiaries, ≥ 67 y, newly diagnosed with ESBC 1992-1994; treating surgeons | 3,851 | 1992-1998 | 35.5%/NA
Mandelblatt, 2002, US | National random sample, Medicare beneficiary women ≥67 y, with newly diagnosed primary, stage I–II BC | 1,833 | 1994 | 33%/Race/ethnicity: Black: 31%; White: 35%
Bickell, 2000, US | Convenience sample women BC stage I–II, receiving definitive surgical treatment in 4 hospitals in NY | 723 | 1995-1996 | 59%/NA
Keating, 2001, US | Convenience sample women diagnosed with stage I & II BC at 17 hospitals (MA) & 30 hospitals (MN) | 792 (MA); 1,634 (MN) | 1993-1995 | 73.8% (MA) vs. 48% (MN)/NA
Guadagnoli, 1998b, US | Convenience sample women BC stage I or II in hospitals of 2 US states (MA & MN) | 1,299 (MA); 836 (MN) | 1993-1995 | 74% (MA) vs. 48% (MN)/ Age (vs. <50 y)(OR): 50–59 y: NS (MA & MN); 60–69 y: NS (MA & MN); 0.7 NS (MN); 70–79 y: NS (MA); S (MN); ≥80 y: NS (MA); S (MN) /Residence (vs. non-urban): Urban: NS (MA); S (MN)/Income: <$40,000: 0.7 NS (MA & MN)/HMO member: NS (MA & MN)/Education (% High school): 70–79: NS (MA & MN); 80–89: NS (MA & MN) ≥ 90: NS (MA & MN)
Lazovich, 1999, US | National population-based sample women stage I–II diagnosed 1983-1995, 9 US regions | 109,880 | 1990-1995 | NR/Age: <50 y: 48%; 50–59 y: 49%; 60–69 y: 44.6%; 70–79 y: 39.2%; ≥80 y: 34.7%/Race: White: 44.5%; Non-white: 43.1%
White, 2003, US | Convenience sample women stage I–II BC receiving their diagnosis and initial course of treatment at any of 842 hospitals | 16,643 | 1994 | 42.6%/Age: < 70 y: 46%; ≥ 70 y: 34%/ Race/ethnicity: White: 43%; Black + Hispanic: 44%/Payer: Government: 36.9%; Private: 48.4% S
Morrow, 2001, US
Brenin, 1999, US | National convenience sample women BC, stage I or II treated in 1994, in US hospitals | 17,151 | 1994 | 44.5%/NA
Hebert-Croteau, 1999, Canada | Random sample newly diagnosed stage I–II BC women ≥50 y treated in Quebec | 1,174 | 1993-1994 | NR/Age: 50–69 y: 90.9%; ≥70 y: 80.1%
Lazovich, 1997, US | National population-based sample women ESBC stage I or II diagnosed 1983-1993, 13 western Washington counties | 13,541 | 1990-1993 | NR (Stage: I: 54.9%; II: 35.2%) /Age: < 50 y: 52.1%; 50–59 y: 54.9%; 60–69 y: 47.4%; 70–79 y: 39.1%; ≥ 80 y: 31.7%/Education: Lowest tertile: 44.9%; Middle tertile: 49.9%; Highest tertile: 50.9% S
Mor, 2000, US | Random sample women > 60 y with BC stage I or II diagnosed at 6 hospitals in Providence, RI | 350 | 1992-1997 | 64.1%/NA
Tyldesley, 2003, Canada | Population-based samples women ESBC eligible for BCS in North American population (DCIS; stage I–IIIA) | NR | NR | NR (Stage: DCIS: 63%; I: 57%; II: 52%; IIIA: 27%)/NA
Cheung, 1999, Hong Kong | Convenience sample of women with operable primary BC < 5 cm; attended by the author. For BCS, tumor size < 3 cm | 100 | NR | 32%/NA
Ottevanger, 2002, Netherlands | Population-based sample premenopausal women, node (+) BC; stages II to IIIA treated from 1988-1992 in 9 hospitals | 254 | 1993-1998 | 55.5%/NA
Engel, 2002, Germany | Convenience sample women with any stage BC residing in 6 regions in Germany | NR (Total= 8,661) | 1996-1998 | NR/NA (No breakdown for stages for which BCS is indicated)
Hislop, 2003, Canada | Population-based sample women any stage BC diagnosed in British Columbia. | NR (Total = 1,159) | 1995 | NR (Incomplete breakdown for M0 invasive pts for whom BCS is indicated)/Age: < 40 y: 42%; 40–49 y: 51%; 50–59 y: 58%; 60–69 y: 50%; 70–79 y: 42%; ≥ 80 y: 41%/By family income: <$35,000: 44%; $35,000–$44,999: 46% $45,000–$54,999: 46%; ≥$55,000: 55%
Lagorreta, 2000, US | Convenience sample women ≥ 21 y with invasive carcinoma; DCIS; stages 0–II; tumor ≤ 5 cm; eligible for BCS, California | 748 | 1994-1996 | 63%/NA
Solin, 1999, US | Convenience sample women ≥ 65 y, newly diagnosed stage 0–II BC < 5cm | 95 | 1993-1994 | 65%/NA

Summary Table 9. Surgery

Summary Table 9. Surgery

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate number of therapeutic operations (≤ 2) for women having breast-conserving surgery ^ IV ^
Cheung, 1999, Hong Kong | Convenience sample of women with operable primary BC < 5 cm; attended by the author. For BCS, only tumor size < 3 cm | 100 | NR | 100% (Standard: 90%)/NA
Appropriate use of mastectomy ^ IV ^
Ottevanger, 2002, Netherlands | Population-based sample premenopausal women, node (+) BC; stages II to IIIA treated from 1988-1992 in 9 hospitals | 254 | 1993-1998 | 44.5%/NA
Cheung, 1999, Hong Kong | Convenience sample of women with operable primary BC < 5 cm; attended by the author | 100 | NR | 68%/NA

Summary Table 10. Surgery

Summary Table 10. Surgery

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of axillary lymph node dissection ^ IV ^
Craft, 2000, Australia | Convenience sample women newly diagnosed primary localized invasive BC treated in Australian capitol territory | 190 | 1997-1998 (14 mo) | 91%/NA
Bickell, 2000, US | Convenience sample women BC stage I–II, receiving definitive surgical treatment in 4 hospitals in NY | 723 | 1995-1996 | 87%/NA
Guadagnoli, 1998a, US | Convenience sample women ESBC (stage I or II) in 2 states of US (MA & MN) | 2,575 | 1993-1995 | 81% (MA) vs. 94% (MN)/Age (vs. < 50y) (OR): 50–59 y: NS (MA & MN); 60–69 y: NS (MA & MN); 70–79 y: S (MA &MN); >80 y: S (MA &MN)
Brenin, 1999, US | National convenience sample women BC, stage I or II treated in 1994, in US hospitals | 17,151 | 1994 | 93.2%/Age: < 70 y: 97%; > 70 y: 86%/Payer: Private vs. Government: OR 1.4 S
Hebert-Croteau, 1999, Canada | Random sample newly diagnosed stage I–II BC women ≥50 y treated in Quebec | 1,174 | 1993-1994 | NR/Age: 50–69 y: 82.4%; ≥70 y: 46.9%
Edge, 2002, US | Convenience sample women ≥67 y stage T1–T2 (N0N1) M0, newly diagnosed invasive BC who underwent BCS | 464 | 1995-1997 | 63.4%/Age: 67–69 y: 84%; 70–74 y: 73%; 75–79 y: 62%; ≥80 y: 33% S/Race/ethnicity: White: 64%; Black: 60% NS/ Education: < high school: 60%; ≥ high school: 66%/Payer: HMO: 64%; Private: 65%
Mandelblatt, 2002, US | National random sample, Medicare beneficiary women ≥67 y, with newly diagnosed primary, stage I–II | 1,833 | 1994 | 86%/Race/ethnicity: Black: 88%; White: 84%
Nattinger, 2000, US | National population-based sample women ≥30 y at the time of first diagnosis of invasive local or regional unilateral BC | 144,759 | 1995 | 97.3%/NA

Summary Table 11. Radiotherapy

Summary Table 11. Radiotherapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of radiotherapy ^ IV ^
Ray-Coquard, 1997, France | Random sample women with localized BC (DCIS to nonmetastatic invasive carcinoma) in a cancer center in Rhone Alpes Area | 99 | 1995 | 93%/NA
Foroudi, 2002, Canada | Population-based sample women BC eligible for RT from North American population | NR | NR | 66.4% (Initial RT: 57.3%; Late RT: 9.1%; Stage: IV, brain metastases at dx: 1.8%; IV; symptomatic bone metastasis at dx: 10%; IV, delayed symptoms bone metastasis: 10.4–21.7%; IV, delayed brain metastasis: 4.8–10%; IV, delayed cord compression: 0.4–0.8%)/NA
Solin, 1999, US | Convenience sample women ≥ 65 y, newly diagnosed stage 0–II BC < 5cm | DCIS: 5 Stage I & II: 57 | 1993-1994 | NR (Stage: DCIS: 60%; stage I & II: 91%)/NA

Summary Table 12. Radiotherapy

Summary Table 12. Radiotherapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use: Women treated with breast-conserving surgery should begin radiation therapy within 6 weeks of completing either of the following: the last surgical procedure on the breast (including reconstructive surgery that occurs within 6 weeks of primary resection) or chemotherapy, if the patient receives adjuvant chemotherapy, unless wound complications prevent the initiation of treatment ^ IV ^
McGlynn, 2003, US | Random sample of women living in 12 US metropolitan areas | 10 | 1998-2000 | 45.3%/NA
Appropriate use of radiotherapy after breast-conserving surgery ^ IV ^
Ottevanger, 2002, Netherlands | Population-based sample premenopausal women, node (+) BC; stages II to IIIA treated from 1988-1992 in 9 hospitals | 141 | 1993-1998 | 100%/NA
Engel, 2002, Germany | Convenience sample women with any stage BC residing in 6 regions in Germany | NR (Total= 8,661) | 1996-1998 | NR/NA (No breakdown for stages for which BCS is indicated)
Foroudi, 2002, Canada | Population-based sample women BC eligible for RT from North American population | NR | NR | NR (Stage: In situ; moderate risk: 37.7%; I (pN0): 57%; II (pN0): 52.2%; II (pN1): 31.1%; IIIA: 27.8%)/NA
Hislop, 2003, Canada | Population-based sample women any stage BC diagnosed in British Columbia | NR (Total = 1,159) | 1995 | NR (Stage: M0 invasive: 38% DCIS: 13% [Incomplete breakdown for M0 invasive pts for whom BCS is indicated])/ Family income: <$35,000: 100%; $35,000–44,999: 80%; $45,000–54,999: 89%; ≥$55,000: 82%
Mandelblatt, 2001, US | National random sample, Medicare beneficiaries, ≥ 67 y, newly diagnosed with ESBC 1992 -1994; treating surgeons | 3,851 | 1992-1998 | 72.1%/NA
Craft, 2000, Australia | Convenience sample women newly diagnosed primary localized invasive BC treated in Australian capitol territory | 87 | 1997-1998 (14 mo) | 98%/NA
Bickell, 2000, US | Convenience sample women BC stage I–II, receiving definitive surgical treatment in 4 hospitals in NY | 723 | 1995-1996 | 81%/NA
Lazovich, 1999, US | National population-based sample women stage I–II diagnosed 1983-1995, 9 US regions | 109,880 | 1990-1995 | 81.5%/Age: < 50 y: 82.4%; 50–59 y: 86.1%; 60–69 y: 86.6%; 70–79 y: 80.2%; ≥ 80 y: 48.5% S/Race/ethnicity: White: 81.7%; Non-white: 80.7%
Guadagnoli, 1998a, US | Convenience sample women ESBC (stage I or II) in 2 states of US (MA & MN) | 2,575 | 1993-1995 | 84% (MA) vs. 86% (MN)/Age (vs. < 50 y) (OR): 50–59 y: S (MA); NS (MN); 60–69 y: NS (MA &MN); 70–79 y: S (MA); NS (MN); >80 y: S (MA & MN)
Appropriate use: Women treated with breast-conserving surgery should begin radiation therapy within 6 weeks of completing either of the following: the last surgical procedure on the breast (including reconstructive surgery that occurs within 6 weeks of primary resection) or chemotherapy, if the patient receives adjuvant chemotherapy, unless wound complications prevent the initiation of treatment ^ IV ^
Guadagnoli, 1998b, US | Convenience sample women BC stage I or II in hospitals of 2 US states (MA & MN) | 1,299 (MA); 836 (MN) | 1993-1995 | 84% (MA) vs. 86% (MN)/NA
Hebert-Croteau, 1999, Canada | Random sample newly diagnosed stage I–II BC women ≥50 y treated in Quebec | 1,174 | 1993-1994 | NR/Age: 50–69 y: 89.6%; ≥70 y: 59%
Lazovich, 1997, US | National population-based sample women ESBC stage I or II diagnosed 1983-1993, 13 western Washington counties | 13,541 | 1990-1993 | 94.1%/NA
White, 2003, US | Convenience sample women stage I–II BC receiving their diagnosis and initial course of treatment at any of 842 hospitals | 7,097 | 1994 | 85.9%/Age: <70 y: 88.4%; ≥70 y: 78.9%/Race/ethnicity: White: 86.3%; Black-Hispanic: 83.2%/ Payer: Government: 83.3%; Private: 88.6% S
Morrow, 2001, US
Edge, 2002, US | Convenience sample women ≥67 y stage T1–T2 (N0N1) M0, newly diagnosed invasive BC who underwent BCS | 464 | 1995-1997 | 77.8%; with ALND: 54.7%/NA
Mor, 2000, US | Convenience sample of women >60 y with BC stage I or II diagnosed at 6 hospitals in Providence, RI | 350 | 1992-1997 | 70.4 %/Age: 60–69 y: 94%; 70–79 y: 83%; ≥ 80 y: 34% S
Solin, 1999, US | Convenience sample women ≥ 65 y, newly diagnosed stage 0–II BC < 5cm | 62 | 1993-1994 | 89%/NA
Mandelblatt, 2002, US | National random sample, Medicare beneficiary women ≥67 y, with newly diagnosed primary, stage I–II BC | 599 | 1994 | 66.6%/Race/ethnicity: Black: 61%; White: 72.2% (S)
Nattinger, 2000, US | National population-based sample women ≥30 y at the time of first diagnosis of invasive local or regional unilateral BC | 144,759 | 1995 | 65%/NA

Summary Table 13. Radiotherapy

Summary Table 13. Radiotherapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Quality of radiotherapy after breast-conserving surgery (following guidelines) ^ IV ^
Jackson, 1999, Canada | Population-based sample women receiving radical or adjuvant postoperative RT treatments for BC, 3 clinics in British Columbia | 9,351 | 1985-1996 | 95% (69%–99.5%)/NA
Appropriate use of radiotherapy after mastectomy ^ IV ^
Engel, 2002, Germany | Convenience sample women with any stage BC residing in 6 regions in Germany | NR (Total= 8,661) | 1996-1998 | NR (Region: 10.4%–32.2%)/NA
Jackson, 1999, Canada | Population-based sample women receiving radical or adjuvant postoperative RT treatments for BC, 3 clinics in British Columbia | 9,351 | 1985-1996 | 82.5% (4%–95.5%)/NA
Foroudi, 2002, Canada | Population-based sample women BC eligible for RT from North American population | NR | NR | NR (Stage: I (pN0): 0.6–0.8%; II (pN0): 0.77–0.83%; II (pN1); <4N(+):0. 3%; II (pN1); >3N(+): 5.7–6.1%; IIIA, < 4N(+): 0.24–0.35%; IIIA; >3N(+): 5.1–7.4%; IIIB (pT4 or pN3): 42%)/NA

Summary Table 14. Radiotherapy

Summary Table 14. Radiotherapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Quality of radiotherapy via planning on a dedicated simulator ^ IV ^
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 88.9%/Age: <70 y: 89%; ≥70 y: 88.8%/Race/ethnicity: White: 89%; Black-Hispanic: 87.7%/ Payer: Government: 89.1%; Private: 88.8%
Quality of radiotherapy: done 5 days/week ^ IV ^
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 97.4%/Age: <70 y: 97.4%; ≥70 y: 97.4%/Race/ethnicity: White: 97.5%; Black-Hispanic: 97.5%/ Payer: Government: 97.1%; Private: 97.1%
Quality of radiotherapy: homogenous dose distribution of radiotherapy ^ IV ^
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 95%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 96.6%/Age: <70 y: 96.6%; ≥70 y: 96.8%/Race: White: 96.6%; Black-Hispanic: 96.5% /Payer: Government: 96.7%; Private: 96.7%
Quality of radiotherapy: use of wedges on tangent breast fields ^ IV ^
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 93.4%/Age: <70 y: 93.3%; ≥70 y: 93.8%/Race/ethnicity: White: 93.5%; Black-Hispanic: 92.1%/ Payer: Government: 93%; Private: 93.8%
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 92.8%/NA

Summary Table 15. Radiotherapy

Summary Table 15. Radiotherapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of radiotherapy on axilla following axillary lymph node dissection, to deal with increased risk of local recurrence (i.e. extracapsular extension; ≥ 4 positive nodes) ^ IV ^
Ottevanger, 2002, Netherlands | Population-based sample premenopausal women, node (+) BC; stages II to IIIA treated from 1988-1992 in 9 hospitals | 85 | 1993-1998 | 84.7%/NA
Jackson, 1999, Canada | Population-based sample women receiving radical or adjuvant postoperative RT treatments for, 3 clinics in British Columbia | 9,351 | 1985-1996 | 75% (3%–92%)/NA
Brenin, 1999, US | National convenience sample women BC, stage I or II, in US hospitals | 899 | 1994 | 53.9%/NA
Appropriate use of parasternal radiotherapy for tumors located in the medial part of breast ^ IV ^
Ottevanger, 2002, Netherlands | Population-based sample premenopausal women, node (+) BC; stages II to IIIA treated from 1988-1992 in 9 hospitals | 114 | 1993-1998 | 49.1%/NA
Appropriate use of palliative radiotherapy for women with progression or recurrence ^ IV ^
Foroudi, 2002, Canada | Population-based sample women BC eligible for RT from North American population; later RT | NR | NR | NR (Stage: I & II (pN0), postmastectomy: 2.9–4.2%;II (pN1); postmastectomy: 0.5%; e III; postmastectomy: 0.39–0.57%)/NA
Regional recurrence needing further surgery or radiotherapy ^ IV ^
Foroudi, 2002, Canada | Population-based sample women BC eligible for RT from North American population; late RT | NR | NR | NR (Stage: DCIS: 0.02–0.1%; DCIS, recur with DCIS or invasive carcinoma: 1.2%; I & II (pN0), postmastectomy: 1.3–1.9%; II (pN1); postmastectomy: 1.35%; III; postmastectomy: 1.2–1.7%; LCIS; recur with DCIS or invasive carcinoma: 0.7%)/NA
Cheung, 1999, Hong Kong | Convenience sample of women with operable primary BC <5 cm; attended by the author | 100 | NR | 0% (Standard at 5 y: <10%)/NA

Summary Table 16. Radiotherapy

Summary Table 16. Radiotherapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Quality of radiotherapy: both tangent fields treated daily ^ IV ^
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 725 | 1995-1996 | 99.9%/NA
Quality of radiotherapy: receiving 4,500–5,000 cGy total breast dose given in 180–200 cGy fractions ^ IV ^
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 725 | 1995-1996 | 99%/NA
Quality of radiotherapy: electron beam breast radiation used ^ IV ^
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 725 | 1995-1996 | 94%/NA

Summary Table 17. Adjuvant systemic therapy

Summary Table 17. Adjuvant systemic therapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of any adjuvant systemic therapy ^ IV ^
Craft, 2000, Australia | Convenience sample women newly diagnosed primary localized invasive BC treated in Australian capitol territory | 99 | 1997-1998 (14 mo) | 96%/NA
Bickell, 2000, US | Convenience sample women BC stage I–II, receiving definitive surgical treatment in 4 hospitals in NY | 723 | 1995-1996 | 78%/Age: < 50 y: 59–87 %; ≥ 50 y: 65–85 %
Hebert-Croteau, 1999, Canada | Random sample newly diagnosed stage I–II BC women ≥50 y treated in Quebec | 1,174 | 1993-1994 | NR/Age: 50–69 y: 74.2%; ≥70 y: 72.1%
Silliman, 1999, US | Convenience sample women ≥55 y newly diagnosed stage I or II BC treated 1 center in Boston | 303 | NR | 67.3% (HT: 76%; CT: 13%; HT + CT: 11%)/ Income: ≤U$14,999: 64%; 15,000–29, 999: 60%; 30,000–49,999: 77%; ≥50,000: 73%/Education: < high school: 60%; high school: 68%; some college: 64%; college: 72%
Mor, 2000, US | Convenience sample of women >60 y with BC stage I or II diagnosed between 1992 - 1997 at 6 hospitals in Providence, RI | 350 | 1992-1997 | 81.9%/Age: 60–69 y: 88%; 7–79 y: 82%; ≥ 80 y: 77% S
Guadagnoli, 1997, US | Convenience sample postmenopausal women newly diagnosed ESBC node (+); stage I–II, 30 hospitals in MN | 632 | 1993 | 71%/Age: 50–59 y: 61%; 60–69 y: 70%; 70–79 y: 81%; >80y: 74% S

Summary Table 18. Adjuvant systemic therapy

Summary Table 18. Adjuvant systemic therapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use: Women with invasive breast cancer that is node-positive, or node-negative and primary tumor ≥1 cm, should be treated with adjuvant systemic therapy to include combination chemotherapy (and/or tamoxifen, 20 mg/d) ^ IV ^
McGlynn, 2003, US | Random sample of women living in 12 US metropolitan areas | 13 | 1998-2000 | 85.1%/NA
Appropriate use of any adjuvant systemic therapy in women with node (+) breast cancer ^ IV ^
Harlan, 2002, US | Random sample from population-based databases women stage I, II & IIIA BC diagnosed in 1987-1991 & 1995 | 7,724 | 1987-1991 & 1995 | 70%/Age: <51 y: 82%; 51–64 y: 73%; ≥65 y: 63%
Guadagnoli, 1997, US | Convenience sample postmenopausal women newly diagnosed ESBC; stage I–II, 30 hospitals in MN | 632 | 1993 | 92%/Age: 50–59 y: 93%; 60–69 y: 96%; 70–79 y: 89%; >80y: 85% NS
Appropriate use of any adjuvant systemic therapy in women with node (-) breast cancer ^ IV ^
Harlan, 2002, US | Random sample from population-based databases women stage I, II & IIIA BC diagnosed in 1987-1991 & 1995 | 7,724 | 1987-1991 & 1995 | 53%/Age: <51 y: 45%; 51–64 y: 46%; >65 y: 41% NS/ By Race/ethnicity: White: 44%; Black: 40%; Other: 45%
Guadagnoli, 1997, US | Convenience sample postmenopausal women newly diagnosed ESBC; stage I–II, 30 hospitals in MN | 632 | 1993 | 62%/Age: 50–59 y: 73%; 60–69 y: 67%; 70–79 y: 56%; >80y: 36% S

Summary Table 19. Adjuvant systemic therapy

Summary Table 19. Adjuvant systemic therapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of adjuvant systemic therapy after breast-conserving surgery ^ IV ^
Edge, 2002, US | Convenience sample women ≥67 y stage T1–T2 (N0N1) M0, newly diagnosed invasive BC who underwent BCS | 464 | 1995-1997 | 70.7% (CT: 10.1%; Tamoxifen: 89.9%)/NA
White, 2003, US | Convenience sample women BC node (+) stage I–II diagnosed in 1994 | 16,643 | 1994 | 84.1%/Age: <70 y: 84.9–88.7%; ≥70 y: 72%/Race/ethnicity: White: 85.3%; Black-Hispanic: 78.7%/ Payer: Government: 78.9%; Private: 87.6% S

Summary Table 20. Adjuvant systemic therapy

Summary Table 20. Adjuvant systemic therapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of tamoxifen ^ IV ^
Cheung, 1999, Hong Kong | Convenience sample of women with operable primary BC <5 cm; attended by the author | 100 | NR | 28%/NA
Guadagnoli, 1998a, US | Convenience sample women ESBC (stage I or II) in 2 states of US (MA & MN) | 2,575 | 1993-1995 | 63% (MA) vs. 59% (MN)/NA
Ray-Coquard, 1997, France | Random sample women with localized BC (DCIS to nonmetastatic invasive carcinoma) in a cancer center in Rhone Alpes Area | 99 | 1995 | 94%/NA
Mandelblatt, 2002, US | National random sample, Medicare beneficiary women ≥67 y, with newly diagnosed primary, stage I–II BC | 1,833 | 1994 | 62%/Race/ethnicity: Black: 58% (S); White: 66%
Cornfeld, 2001, US | Convenience sample women BC node (+) treated in the private practice of 11 oncologists | 220 | 1999-2000 (9 mo) | 100%/NA

Summary Table 21. Adjuvant systemic therapy

Summary Table 21. Adjuvant systemic therapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of tamoxifen in premenopausal women with node (-), intermediate risk, breast cancer ^ IV ^
Palazzi, 2002, Italy | Convenience sample women ESBC, indication of RT after BCS for infiltrating carcinoma & known axillary LN status | 1,547 | 1997 | 33%/NA
Appropriate use of tamoxifen in postmenopausal women with node (-), intermediate risk, breast cancer ^ IV ^
Palazzi, 2002, Italy | Convenience sample women ESBC, indication of RT after BCS for infiltrating carcinoma & known axillary LN status | 1,547 | 1997 | 59%/NA
Guadagnoli, 1997, US | Convenience sample postmenopausal women newly diagnosed stage I–II BC, 30 hospitals (MN) | 632 | 1993 | 51%/Age: 50–59 y: 52%; 60–69 y: 55%; 70–79 y: 51%; >80y: 34% S
Appropriate use of tamoxifen in postmenopausal women with node (-), high risk, estrogen receptor (+), breast cancer ^ IV ^
Sawka, 1997, Canada | Population- based women BC node (-) diagnosed in 1991, British Columbia | 932 | 1993-1998 | NR/Age: 50–65%: 62.3%; >65 y: 56.5%
Palazzi, 2002, Italy | Convenience sample women ESBC, indication of RT after BCS for infiltrating carcinoma & known axillary LN status | 1,547 | 1997 | 59%/NA
Appropriate use of tamoxifen in postmenopausal women with node (+), estrogen receptor (+) breast cancer ^ IV ^
Engel, 2002, Germany | Convenience sample women with any stage BC residing in 6 regions in Germany | NR (Total= 8,661) | 1996-1998 | NR (Region: 30.1%–61.5%)/NA
Palazzi, 2002, Italy | Convenience sample women ESBC, indication of RT after BCS for infiltrating carcinoma & known axillary LN status | 1,547 | 1997 | 40%/NA

Summary Table 22. Adjuvant systemic therapy

Summary Table 22. Adjuvant systemic therapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of chemotherapy and hormone therapy (tamoxifen) ^ IV ^
Engel, 2002, Germany | Convenience sample women with any stage BC residing in 6 regions Germany; node (+); HR (+); postmenopausal | NR (Total = 8,661) | 1996-1998 | NR (Region: 9.1%–32.2%)/NA
Sawka, 1997, Canada | Population- based women BC node (-) diagnosed in 1991, British Columbia | 932 | 1993-1998 | 6.6%/NA
Du, 2003, US | Population-based sample women BC ≥20 y stage I–IIIA treated & registered in New Mexico tumor registry | 5,101 | 1991-1997 | 9.6%/Age: <45 y: 15.8%; 45–49 y: 17%; 50–54 y: 18.5%; 55–59 y: 11.7%; 60–64 y: 8%; 65–69 y: 5.4%; 70–74 y: 4%; ≥75 y: 0.8%
Appropriate use of chemotherapy and hormone therapy (tamoxifen) in premenopausal women, node (+), hormone receptor (+), breast cancer ^ IV ^
Engel, 2002, Germany | Convenience sample women with any stage BC residing in 6 regions in Germany | NR (Total = 8,661) | 1996-1998 | NR (Region: 10.3%–57.1%)/NA

Summary Table 23. Adjuvant systemic therapy

Summary Table 23. Adjuvant systemic therapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of chemotherapy ^ IV ^
Du, 2003, US | Population-based sample women BC ≥20 y stage I–IIIA treated & registered in New Mexico tumor registry | 5,101 | 1991-1997 | 28.7%/Age: <45 y: 66%; 45–49 y: 54.9%; 50–54 y: 44.2 %; 55–59 y: 31%; 60–64 y: 18.1%; 65–69 y: 12.3%; 70–74 y: 7.1%; >75 y: 3.4%
Guadagnoli, 1998a, US | Convenience sample women ESBC (stage I or II) in 2 states of US (MA & MN) | 2,575 | 1993-1995 | 97% (MA) vs. 94% (MN)/NA
Ray-Coquard, 1997, France | Random sample women with localized BC (DCIS to nonmetastatic invasive carcinoma) in a cancer center in Rhone Alpes Area | 99 | 1995 | 85%/NA
Cheung, 1999, Hong Kong | Convenience sample of women with operable primary BC <5 cm; attended by the author | 100 | NR | 30%/NA
DeMichele, 2003, US | Convenience sample women BC ≥50 y evaluated at UPCC 1993-1997 & eligible for adjuvant CT | Eligible: 208; Non-eligible: 132 | 1993-1997 | 74%; Non-eligible received: 11%/Age: 50–59 y: 74%; 60–69 y: 74%; 70–86 y: 70%
Du, 2001, US | Population-based sample women BC ≥65 y; stage I–IV (use of CT within 6 mo of Dx) | 5,697 | 1991-1996 | 12.4%/Age: 65–69 y: 20.5%; 70–74 y: 13.9%; 75–79 y: 8.7%; ≥80 y: 3.3%
Mandelblatt, 2002, US | National random sample, Medicare beneficiary women ≥67 y, with newly diagnosed primary, stage I –II BC | 1,833 | 1994 | 9%/Race/ethnicity: Black: 11% S; White: 7%

Summary Table 24. Adjuvant systemic therapy

Summary Table 24. Adjuvant systemic therapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of chemotherapy in women with node (-), high risk, estrogen receptor (-), breast cancer ^ IV ^
Sawka, 1997, Canada | Population- based women BC node (-) diagnosed in 1991, British Columbia | 932 | 1993-1998 | NR/Age: <50 y: 78.6%; 50–65 y: 19.1%
Palazzi, 2002, Italy | Convenience sample women ESBC, indication of RT after BCS for infiltrating carcinoma & known axillary LN status | 1,547 | 1997 | 59%/NA
Du, 2001, US | Population-based sample women BC ≥ 65 y; stage I–IV (use of CT within 6 mo of Dx) | 5,697 | 1996 | 17.9%/NA
Appropriate use of chemotherapy in women with node (-), estrogen receptor (+), breast cancer ^ IV ^
Du, 2001, US | Population-based sample women BC ≥ 65 y; stage I–IV (use of CT within 6 mo of Dx) | 5,697 | 1996 | 2%/NA

Summary Table 25. Adjuvant systemic therapy

Summary Table 25. Adjuvant systemic therapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of chemotherapy in premenopausal women with node (-), high risk, estrogen receptor (+), breast cancer ^ IV ^
Palazzi, 2002, Italy | Convenience sample women ESBC, indication of RT after BCS for infiltrating carcinoma & known axillary LN status | 1,547 | 1997 | 55%/NA
Appropriate use of chemotherapy in premenopausal women with node (+), estrogen receptor (-), breast cancer ^ IV ^
Engel, 2002, Germany | Convenience sample women with any stage BC residing in 6 regions in Germany | NR (Total = 8,661) | 1996-1998 | NR (Region: 63.6%–92.3%)/NA
Palazzi, 2002, Italy | Convenience sample women ESBC, indication of RT after BCS for infiltrating carcinoma & known axillary LN status | 1,547 | 1997 | 90%/NA

Summary Table 26. Adjuvant systemic therapy

Summary Table 26. Adjuvant systemic therapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of chemotherapy in postmenopausal women with node (+), estrogen receptor (-), breast cancer ^ IV ^
Engel, 2002, Germany | Convenience sample women with any stage BC residing in 6 regions in Germany | NR (Total = 8,661) | 1996-1998 | NR (Region: 38.5%–69.6%)/NA
Palazzi, 2002, Italy | Convenience sample women ESBC, indication of RT after BCS for infiltrating carcinoma & known axillary LN status | 1,547 | 1997 | 81%/NA
Du, 2001, US | Population-based sample women BC ≥ 65 y; stage I–IV (use of CT within 6 mo of Dx) | 5,697 | 1996 | 61.5%/NA
Appropriate use of chemotherapy in postmenopausal women with node (+), estrogen receptor (+), breast cancer ^ IV ^
Du, 2001, US | Population-based sample women BC ≥ 65 y; stage I–IV (use of CT within 6 mo of Dx) | 5,697 | 1996 | 27%/NA

Summary Table 27. Adjuvant systemic therapy

Summary Table 27. Adjuvant systemic therapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of chemotherapy in women <50 years of age with node (+), breast cancer ^ IV ^
Craft, 2000, Australia | Convenience sample women newly diagnosed primary localized invasive BC treated in Australian capitol territory | 27 | 1997-1998 (14 mo) | 100%/NA
Appropriate use of chemotherapy &/or ovarian ablation in premenopausal women with node (+), estrogen receptor (+), breast cancer ^ IV ^
Engel, 2002, Germany | Convenience sample women with any stage BC residing in 6 regions in Germany | NR (Total = 8,661) | 1996-1998 | NR (Region: 42.9%–84.6%)/NA
Palazzi, 2002, Italy | Convenience sample women ESBC, indication of RT after BCS for infiltrating carcinoma & known axillary LN status | 1,547 | 1997 | NR (CT 73%; CT + OA: 18%; OA: 4%)/NA

Summary Table 28. Adjuvant systemic therapy

Summary Table 28. Adjuvant systemic therapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate decision not to provide adjuvant systemic therapy for women node (-), low risk, breast cancer ^ IV ^
Sawka, 1997, Canada | Population- based women BC node (-) diagnosed in 1991, British Columbia | 932 | 1993-1998 | 84.9%/Age: 50–65 y: 90.3%; >65 y: 85.9%
Palazzi, 2002, Italy | Convenience sample women ESBC, indication of RT after BCS for infiltrating carcinoma & known axillary LN status | 1,547 | 1997 | 69%/NA
Harlan, 2002, US | Random sample from population-based databases women stage I, II & IIIA BC diagnosed in 1987-1991 & 1995 | 7,724 | 1987-1991 & 1995 | 52.2% (1995)/NA
Appropriate decision not to provide adjuvant systemic therapy for women > 65 years of age with high risk, estrogen receptor (-), breast cancer ^ IV ^
Sawka, 1997, Canada | Population- based women BC node (-) diagnosed in 1991, British Columbia | 932 | 1993-1998 | 82.1%/NA

Summary Table 29. Adjuvant systemic therapy

Summary Table 29. Adjuvant systemic therapy

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Quality of chemotherapy: proper doses administered (≥ 85% dose intensity [DI] & relative dose intensity [RDI]) of CMF ^ IV ^
Ottevanger, 2002, Netherlands | Population-based sample premenopausal women, node (+) BC; stages II to IIIA treated from 1988-1992 in 9 hospitals | 254 | 1993-1998 | 78.9% (DI); 58.7% (RDI)/NA
Availability of office procedure manual used for chemotherapy administration ^ IV ^
Cornfeld, 2001, US | Convenience sample women BC treated in the private practice of 11 oncologists | 220 | 1999-2000 (9 mo) | 100%/NA

Summary Table 30. QOL and patient satisfaction relating to treatment

Summary Table 30. QOL and patient satisfaction relating to treatment

Author, year, Location | Sample description | No. Eligible | Measurement Period | Results
Overall changes in QOL over time, before & after radiotherapy ^ Iac ^
Jansen, 2000, Netherlands | Convenience sample women ESBC underwent surgery (BCS or mastectomy) | 46 | 1997-1999 | 38% (worse); 40% (stable); 22% (improved)/NA
Hassey 2000, US | Convenience sample women ESBC beginning a course of RT after BCS at a hospital in Northeast. 21–45 y; newly diagnosed; not undergoing CT or HT | 23 | 6 mo | NR (NS changes over time in QLI scales)/NA

Summary Table 31. QOL and patient satisfaction relating to treatment

Summary Table 31. QOL and patient satisfaction relating to treatment

Author, year, Location | Sample description | No. Eligible | Measurement Period | Results
Change in QOL in women with metastatic breast cancer ^ Iac ^
Osoba, 1999, Canada & US | Convenience sample women progressive HER-2- overexpressing metastatic BC had been previously treated with CT (phase II) or had not have previous cytotoxic CT (phase III) received trastuzumab | 154 | 32 wks (NR) | 100%/Phase of study: Phase II: no apparent worsening of scores; Phase III: NS changes
Perez, 2001, New Zealand UK | Convenience sample women presenting at Dunedin Hospital, NZ, with metastatic symptoms BC | 38 | 1 y (NR) | NR/NA
Women with a significant improvement in QOL in clinical phases of breast cancer ^ Iac ^
Chie, 1999, China | Convenience sample women diagnosed or treated for BC in the breast surgery; RT & oncology outpatients departments; or in general surgical wards of National Taiwan University Hospital | 115 | 1997 (2 mo) | NR/NA
Change in QOL by time and treatment arm in postmenopausal, node (-) breast cancer women who underwent adjuvant therapy ^ Ia ^
Bernhard, 1997, Netherlands | Convenience sample pre- & postmenopausal women with operable BC | 312 | 1993-1995 | NS in scales of physical well-being; mood; appetite at 1, 3 & 6 mo/NA

Summary Table 32. QOL and patient satisfaction relating to treatment

Summary Table 32. QOL and patient satisfaction relating to treatment

Author, year, Location | Sample description | No. Eligible | Measurement Period | Results
Change in QOL over time ^ Iac ^
Molenaar, 2001, Netherlands | Convenience sample women newly diagnosed with stage I & II BC eligible for either BCS or mastectomy in 3 Dutch hospitals | 167 | 1996-1998 | Generic QOL scale & specific QOL scale: positive effect (CDROM) 0, 3 & 9 mo; ND/NA
Bower, 2000, US | Convenience sample women ESBC (stage 0–II); diagnosed <5 y; completed adjuvant therapy; currently disease-free; only treated with tamoxifen (cancer survivors) | 1,957 | 1994-1997 | NR/Energy/fatigue: 60; Physical functioning: 80.35; Role limitation- physical: 75.80; Emotional well-being: 75; Role limitation-emotional: 77; Social functioning: 86; Bodily pain: 78.60; General health: 73
Frazer, 1998, US | Convenience sample women ESBC diagnosed in 1993 and treated by surgery and HT at MDACCO, Orlando, Florida | 70 | 1993-1996 | NS changes over time in all the subscales and overall/NA
Mor, 1994, US | Convenience sample women BC from 2 research trials | 262 | NR | NR/Age: 24–54 y: 67.6%; >55 y: 71%

Summary Table 33. QOL and patient satisfaction relating to treatment

Summary Table 33. QOL and patient satisfaction relating to treatment

Author, year, Location | Sample description | No. Eligible | Measurement Period | Results
Satisfaction of women with breast cancer with the treatment choice ^ Iac ^
Molenaar, 2001, Netherlands | Convenience sample women newly diagnosed with stage I & II BC eligible for either BCS or mastectomy in 3 Dutch hospitals | 167 | 1996-1998 | (+) Effect (CDROM) 0, 3 & 9 mo; ND/NA
Keating, 2001, US | Convenience sample women diagnosed with stage I & II BC at 17 hospitals (MA) & 30 hospitals (MN) | 792 (MA); 1,634 (MN) | 1993-1995 | Very satisfied: 80% (MA) vs. 76% (MN)/NA
Participation of women with breast cancer in decision-making as much as they wanted ^ IV ^
Keating, 2001, US | Convenience sample women diagnosed with stage I & II BC at 17 hospitals (MA) & 30 hospitals (MN) | 792 (MA); 1,634 (MN) | 1993-1995 | 83% (MA) vs. 81% (MN)/NA
Received enough information about surgery and radiotherapy ^ IV ^
Keating, 2001, US | Convenience sample women diagnosed with stage I & II BC at 17 hospitals (MA) & 30 hospitals (MN) | 792 (MA); 1,634 (MN) | 1993-1995 | 80% (MA) vs. 80% (MN)/NA

Summary Table 34. General category

Summary Table 34. General category

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Board certified medical doctors in medical oncology ^ IV ^
Cornfeld, 2001, US | Convenience sample women BC treated in the private practice of 11 oncologists | 220 | 1999-2000 (9 mo) | 100%/NA
Documentation of Continuing Medical Education credits for the 2 years preceding audit ^ IV ^
Cornfeld, 2001, US | Convenience sample women BC treated in the private practice of 11 oncologists | 220 | 1999-2000 (9 mo) | 100%/NA

Summary Table 35. General category

Summary Table 35. General category

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Referral to oncologist for treatment ^ IV ^
Bickell, 2000, US | Convenience sample women BC stage I–II, receiving definitive surgical treatment in 4 hospitals in NY | 723 | 1995-1996 | 64%/NA
Women with breast cancer given the opportunity to see a breast cancer specialist nurse ^ IV ^
Cheung, 1999, Hong Kong | Convenience sample women with operable primary BC <5 cm; attended by the author | 100 | NR | 100% (Standard: 100%)/NA
Evidence of discussion about surgical options ^ IV ^
Bickell, 2000, US | Convenience sample women BC stage I–II, receiving definitive surgical treatment in 4 hospitals in NY | 723 | 1995-1996 | NR (Hospital: 65–100%)/NA
Molenaar, 2001, Netherlands | Convenience sample women newly diagnosed with stage I & II BC eligible for either BCS or mastectomy in 3 Dutch hospitals, patient preference measured | 167 | 1996-1998 | 100%

Summary Table 36. General category

Summary Table 36. General category

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
≥90% of women admitted for an operation within 21 days of the surgical decision to operate for therapeutic purposes ^ IV ^
Sauven, 2003, UK | Population-based sample BC women detected by screening in UK, Wales, Scotland & Northern Ireland | 43,500 | 1996-2001 | NR/Overall by y (range): 77–82%
Cheung, 1999, Hong Kong | Convenience sample women with operable primary BC <5 cm; attended by the author | 100 | NR | 93%/NA
McCarthy, 1997,UK | Convenience sample women operable BC, <70 y treated at Nottingham City Hospital's | 83 | 1994 | 90.4%/NA

Summary Table 37. General category

Summary Table 37. General category

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of treatment sequences according to guidelines (including surgery; radiotherapy; chemotherapy; hormone therapy; initial examination; and followup) ^ IV ^
Mor, 2000, US | Convenience sample women >60 y with BC stage I or II diagnosed between 1992 - 1997 at 6 hospitals in Providence, RI | 350 | 1992-1997 | 72.9%/Age: 60–69 y: 89%; ≥80 y: 50% S
Ray-Coquard, 2002, France | Random sample women localized BC (in situ or invasive) treated in the cancer network in Rhone-Alpes region | 346 | 1996 | 36% (Initial examination: 86%; Surgery: 94%; CT: 78%; RT: 77%; HT: 79%; Followup: 81%)/NA
Ray-Coquard, 1997, France | Random sample women with localized BC (DCIS to nonmetastatic invasive BC) in a cancer center in Rhone Alpes Area | 99 | 1995 | 54%/NA
Hislop, 2003, Canada | Population-based sample women any stage BC diagnosed in British Columbia | NR (Total = 1,159) | 1995 | 81% (Extent of disease: LCIS: 78%; DCIS: 71%; Metastatic: 73%; M0 invasive: 83%)/NA

Summary Table 38. General category

Summary Table 38. General category

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key Differences
Appropriate use of definitive locoregional therapy (total mastectomy + axillary lymph node dissection, or, breast-conserving surgery + axillary lymph node dissection + radiotherapy) ^ IV ^
Nattinger, 2000, US | National population-based sample women ≥30 y at the time of first diagnosis of invasive local or regional unilateral BC | 144,759 | 1995 | 78%/NA
Hebert-Croteau, 1999, Canada | Random sample newly diagnosed stage I–II BC women ≥50 y treated in Quebec | 1,174 | 1993-1994 | NR/Age: 50–69 y: 83.5%; ≥70 y: 48.7%
Silliman, 1999, US | Convenience sample women ≥55 y newly diagnosed stage I or II BC treated 1 center in Boston | 303 | NR | 77.2% (Surgery type: BCS + RT: 56%; Mastectomy: 22%)/ Income: ≤U$14,999: 55%; 15,000–29, 999: 85%; 30,000–49,999: 91%; ≥50,000: 87%/Education: < high school: 55%; high school: 75%; some college: 83%; college: 82%
Appropriate use of alternative definitive therapy (radiotherapy after breast-conserving surgery + axillary lymph node dissection or adjuvant treatment) ^ IV ^
Hebert-Croteau, 1999, Canada | Random sample newly diagnosed stage I–II BC women ≥50 y treated in Quebec | 1,174 | 1993-1994 | NR/Age: 50–69 y: 90.9%; ≥70 y: 60.9%
Silliman, 1999, US | Convenience sample women ≥55 y newly diagnosed stage I or II BC treated 1 center in Boston | 303 | NR | 51.8%/Age: 55–64 y: 50%; 65–74 y: 41%; 75–84 y: 9%
Cases not receiving recommended treatment (radiotherapy after breast-conserving surgery or systemic therapy) due to system failure ^ IV ^
Bickell, 2003, US | Convenience sample women ESBC who had treatment underuse; not RT or adjuvant therapy recommended when indicated | 44 | 1998-1999 | 32%/NA
Appropriate use: Women with metastatic cancer should be offered hormonal therapy, chemotherapy, and/or enrollment in a clinical trial with documentation of informed consent, within 6 weeks of the identification of metastases ^ IV ^
McGlynn, 2003, US | Random sample of women living in 12 US metropolitan areas | 4 | 1998-2000 | 82.6%/NA

Summary Table 39. Followup

Summary Table 39. Followup

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Appropriate use: Women with a history of breast cancer should have a yearly mammography ^ IV ^
McGlynn, 2003, US | Random sample of women living in 12 US metropolitan areas | 99 | 1998-2000 | 84.6%/NA
Appropriate use of guidelines for followup surveillance of breast cancer ^ IV ^
Cornfeld, 2001, US | Convenience sample women with nonmetastatic BC treated in the private practice of 11 oncologists | 110 | 1999-2000 (9 mo) | NR (Overall by practice: Physical exam: 100%; Mx: 98%; Gynecologic followup: 76% (30%–100%))/NA
Ray-Coquard, 1997, France | Random sample women with localized BC (DCIS to nonmetastatic invasive carcinoma) in a cancer center in Rhone Alpes Area | 85 | 1995 | 80% (undefined followup)/NA

KEY: Key differences = regarding age, race, ethnicity, or SES; SES = socioeconomic status; NA = not assessed; BC = breast cancer; NR = not reported; DCIS = ductal carcinoma in situ; S = significant; NS = nonsignificant; Mx = mammography; Level Ia = pre-study data indicating consistently sound psychometric properties; Iac = pre- and on-study data indicating consistently sound psychometric properties; IV = no pre- or on-study psychometric data

Summary Table 40. Followup

Summary Table 40. Followup

Author, year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Women with breast cancer developing local recurrence within 5 years after breast-conserving surgery ^ IV ^
Cheung, 1999, Hong Kong | Convenience sample of women with operable primary BC < 5 cm; attended by the author | 100 | NR | 0% (Standard: <10%)/NA
Women with breast cancer developing local recurrence within 5 years after mastectomy ^ IV ^
Cheung, 1999, Hong Kong | Convenience sample of women with operable primary BC < 5 cm; attended by the author | 100 | NR | 2.6% (Standard: <10%)/NA
Appropriate use of prophylactic radiotherapy in women with high risk of flap recurrence ^ IV ^
Cheung, 1999, Hong Kong | Convenience sample of women with operable primary BC < 5 cm; attended by the author | 100 | NR | 2% (36% in mastectomy cases)/NA

Summary Table 41. Pathology reporting/documentation

Summary Table 41. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting gross observation of lesion ^ IV ^
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, in NY state hospitals | 555 | 1999 | 60.5%/NA
Reporting verification tumor size (microscopic) ^ IV ^
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, in NY state hospitals | 555 | 1999 | 63%/NA
Reporting number of positive lymph nodes (microscopic) ^ IV ^
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, NY state hospitals | 220 | 1999 | 98.6%/NA
Reporting nuclear grade (microscopic) ^ IV ^
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, NY state hospitals | 555 | 1999 | 44.3%/NA
Reporting mitotic rate (microscopic) ^ IV ^
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, NY state hospitals | 555 | 1999 | 22.5%/NA
Reporting extent of tubule formation (microscopic) ^ IV ^
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, NY state hospitals | 555 | 1999 | 19.6%/NA

KEY: Key differences = regarding age, race, ethnicity, or SES; SES = socioeconomic status; NA = not assessed; BC = breast cancer; NR = not reported; DCIS = ductal carcinoma in situ; S = significant difference; NS = nonsignificant difference; Mx = mammography; H = Hispanic; Bx = biopsy; ALND = axillary lymph node dissection; TNM = tumor;node;metastasis state; Level Ia = pre-study data indicating consistently sound psychometric properties; Iac = pre- and on-study data indicating consistently sound psychometric properties; IV = no pre- or on-study psychometric data

Summary Table 42. Pathology reporting/documentation

Summary Table 42. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting laterality of surgical specimen (gross examination)^IV^
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, 1999 in NY state hospitals | 555 | 1999 | 99.3%/NA
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range)): 50 – 100%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 98.3%/Age: <70 y: 98.2%; ≥70 y: 98.6%/Race: White: 98.2%; Black-Hispanic: 98.5%/Payer: Government: 98.4%; Private: 98.3%

Summary Table 43. Pathology reporting/documentation

Summary Table 43. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting identification of affected quadrant (gross examination)^IV^
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, in NY state hospitals | 336 | 1999 | 30.7%/NA
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 60%– 100%)/NA
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 97.8%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 21.1%/Age: <70 y: 21.1%; ≥70 y: 21.3%/Race: White: 20.5%; Black-Hispanic: 26.3%/Payer: Government: 22%; Private: 20.4%

Summary Table 44. Pathology reporting/documentation

Summary Table 44. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting the orientation of the pathology specimen (gross examination) ^ IV ^
Wilkinson, 2003, US | Convenience sample women stage I–II infiltrative BC referred to Roswell Park Cancer Institute, after excisional Bx | 83 | 1998-1999 | 25%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 67.1%/Age: <70 y: 68%; ≥70 y: 64.9%/Race: White: 67.6%; Black-Hispanic: 64.2%/Payer: Government: 67.5; Private: 67.1%

Summary Table 45. Pathology reporting/documentation

Summary Table 45. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/Key differences
Reporting size of specimen (gross examination) ^ IV ^
Wilkinson, 2003, US | Convenience sample women stage I–II infiltrative BC referred to Roswell Park Cancer Institute, after excisional Bx. Size in 3 dimensions | 83 | 1998-1999 | 91%/NA
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 90%–100%)/NA

Summary Table 46. Pathology reporting/documentation

Summary Table 46. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/Key differences
Reporting tumor size (macroscopic) ^ IV ^
Wilkinson, 2003, US | Convenience sample women stage I–II infiltrative BC referred to Roswell Park Cancer Institute, after excisional Bx | 83 | 1998-1999 | 40%/NA
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 45.9%/NA
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, in NY state hospitals | 336 | 1999 | 93.5%/NA
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 70%–100%)/NA
Reporting tumor size (microscopic) ^ IV ^
Wilkinson, 2003, US | Convenience sample women stage I–II infiltrative BC referred to Roswell Park Cancer Institute, 1998-1999 after excisional Bx | 83 | 1998-1999 | 90%/NA
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 95.3%/NA

Summary Table 47. Pathology reporting/documentation

Summary Table 47. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/Key differences
Reporting lymph node presence/absence (gross examination) ^ IV ^
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, in NY state hospitals | 555 | 1999 | 83.7%/NA
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 92%/NA
Reporting number of lymph nodes present (gross examination) ^ IV ^
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, in NY state hospitals | 555 | 1999 | 93.5%/NA
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | 100%/NA
Ottevanger, 2002, Netherlands | Population-based sample premenopausal women, node (+) BC; stages II to IIIA treated from 1988-1992 in 9 hospitals | 233 | 1993-1998 | NR (By n nodes: ≥10 nodes: 59.2%; <10 nodes: 40.8%)/NA

Summary Table 48. Pathology reporting/documentation

Summary Table 48. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/Key differences
Reporting nature of specimen (gross examination) ^ IV ^
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 40–100%)/NA
Reporting distance of tumor from nipple (gross examination) ^ IV ^
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 30%–100%)/NA
Reporting description of cut surface of the tumor (gross examination) ^ IV ^
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 10%–80%)/NA
Reporting description of skin (gross examination) ^ IV ^
Appleton,1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 0%–20%)/NA

Summary Table 49. Pathology reporting/documentation

Summary Table 49. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/Key differences
Reporting size of overlying skin (gross examination) ^ IV ^
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | 100%
Reporting description of nipple (gross examination) ^ IV ^
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 50%–100%)/NA
Reporting presence or absence of fascia or skeletal muscle (gross examination) ^ IV ^
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 0%–10%)/NA

Summary Table 50. Pathology reporting/documentation

Summary Table 50. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/Key differences
Reporting involvement of apical lymph nodes (microscopic) ^ IV ^
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 40%–80%)/NA
Reporting size of concurrent ductal carcinoma in situ (microscopic) ^ IV ^
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 33%–100%)/NA
Reporting description of background breast (microscopic) ^ IV ^
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 80%–90%)/NA

Summary Table 51. Pathology reporting/documentation

Summary Table 51. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting ductal carcinoma in situ (DCIS) present/absent (microscopic) ^ IV ^
Wilkinson, 2003, US | Convenience sample women stage I–II infiltrative BC referred to Roswell Park Cancer Institute, after excisional Bx | 83 | 1998-1999 | 71%/NA
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 8.5%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 43.2%/Age: <70 y: 44.8%; ≥70 y: 38.6%/Race: White: 43.3%; Black-Hispanic: 40.8%/Payer: Government: 40.2%; Private: 45.7% S
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR/Overall by y (range): 70%–100%

Summary Table 52. Pathology reporting/documentation

Summary Table 52. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting measurement of macroscopic margins of carcinoma ^ IV ^
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 96.8%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 72.4%/Age: <70 y: 72.5%; ≥70 y: 72.1%/Race: White: 72.5%; Black-Hispanic: 73.5%/Payer: Government: 73.1%; Private: 72.3%
Cheung, 1999, Hong Kong | Convenience sample of women with operable primary BC < 5 cm; attended by the author | 100 | NR | 100%/NA

Summary Table 53. Pathology reporting/documentation

Summary Table 53. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting assessment of microscopic margins ^ IV ^
Wilkinson, 2003, US | Convenience sample women stage I–II infiltrative BC referred to Roswell Park Cancer Institute, after excisional Bx | 83 | 1998-1999 | 94%/NA
Shank, 2000,US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 95.6%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 89.5%/Age: <70 y: 90%; ≥70 y: 88.7%/Race: White: 89.7%; Black-Hispanic: 86.8%/ Payer: Government: 89%; Private: 90.2%
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, in NY state hospitals | 555 | 1999 | 69.4%/NA
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 90%–100%)/NA

Summary Table 54. Pathology reporting/documentation

Summary Table 54. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting carcinoma confirmed microscopically ^ IV ^
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, in NY state hospitals | 555 | 1999 | 100%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 97.8%/Age: <70 y: 97.7%; ≥70 y: 97.9%/Race: White: 97.9% Black-Hispanic: 96.7%/Payer: Government: 98.1%; Private: 97.7%

Summary Table 55. Pathology reporting/documentation

Summary Table 55. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting histological type (microscopic) ^ IV ^
Wilkinson, 2003, US | Convenience sample women stage I–II infiltrative BC referred to Roswell Park Cancer Institute, after excisional Bx | 83 | 1998-1999 | 100%/NA
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 99.7%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 98.8%/Age: <70 y: 98.8%; ≥70 y: 98.7%/Race: White: 98.8%; Black-Hispanic: 99%/Payer: Government: 99%; Private: 98.7%
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, in NY state hospitals | 555 | 1999 | 95.9%/NA
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | 100%

Summary Table 56. Pathology reporting/documentation

Summary Table 56. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting histological grade (microscopic)^IV^
Wilkinson, 2003, US | Convenience sample women stage I–II infiltrative BC referred to Roswell Park Cancer Institute, 1998-1999 after excisional Bx | 83 | 1998-1999 | 90%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 80.6%/Age: <70 y: 81.1%; ≥70 y: 79.3%/Race: White: 80.5%; Black-Hispanic: 79.7%/ Payer: Government: 80.1%; Private: 81.2%
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, in NY state hospitals | 555 | 1999 | 59.1%/NA
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 80%–100%)/NA

Summary Table 57. Pathology reporting/documentation

Summary Table 57. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting lymph-vascular invasion (microscopic)^IV^
Wilkinson, 2003, US | Convenience sample women stage I–II infiltrative BC referred to Roswell Park Cancer Institute, after excisional Bx | 83 | 1998-1999 | 47%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 53.5%/Age: <70 y: 54.3%; ≥70 y: 51.5%/Race: White: 52.9%; Black-Hispanic: 54.4%/ Payer: Government: 51.3%; Private: 54.9% S
Imperato, 2002, US | Random sample Medicare individuals BC total mastectomy + ALND, in NY state hospitals | 555 | 1999 | 45.6%/NA

Summary Table 58. Pathology reporting/documentation

Summary Table 58. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting size of invasive carcinoma (microscopic) ^ IV ^
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 8.5%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 91.8%/Age: <70 y: 91.6%;<70 y: 91.9%/Race: White: 91.7%; Black-Hispanic: 91.2%/Payer: Government: 91.6%; Private: 92%

Summary Table 59. Pathology reporting/documentation

Summary Table 59. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting estrogen receptor status (microscopic) ^ IV ^
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 89%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 91.7%/Age: <70 y: 91.9%; ≥70 y: 91.2%/Race: White: 91.8%; Black-Hispanic: 90.4%/Payer: Government: 91.4%; Private: 92.3%
Reporting progesterone receptor status (microscopic) ^ IV ^
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 86.4%/NA
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 90.6%/Age: <70 y: 90.9%; ≥70 y: 89.7%/Race: White: 90.7%; Black-Hispanic: 89.6%/Payer: Government: 90.1%; Private: 91.4%

Summary Table 60. Pathology reporting/documentation

Summary Table 60. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting specimen inked (microscopic) ^ IV ^
Wilkinson, 2003, US | Convenience sample women stage I–II infiltrative BC referred to Roswell Park Cancer Institute, after excisional Bx | 83 | 1998-1999 | 77%/NA
Reporting Bloom Scarf Richardson scale (tumor grade) (microscopic) ^ IV ^
Wilkinson, 2003, US | Convenience sample women stage I–II infiltrative BC referred to Roswell Park Cancer Institute, after excisional Bx | 83 | 1998-1999 | 6%/NA
Reporting TNM staging (microscopic) ^ IV ^
Wilkinson, 2003, US | Convenience sample women stage I–II infiltrative BC referred to Roswell Park Cancer Institute, after excisional Bx | 83 | 1998-1999 | 9%/NA

Summary Table 61. Pathology reporting/documentation

Summary Table 61. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting distance to the closest margin (microscopic) ^ IV ^
Wilkinson, 2003, US | Convenience sample women stage I–II infiltrative BC referred to Roswell Park Cancer Institute, after excisional Bx | 83 | 1998-1999 | 69%/NA
Appleton, 1998, UK | Convenience sample mastectomy specimens reports of invasive tumor, ALND issued by non-specialist pathologists | 30 (10 for each y) | 1992-1996 | NR (Overall by y (range): 80%–100%)/NA
Reporting pathological extent of primary tumor (microscopic) ^ IV ^
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 99.3%/NA

Summary Table 62. Pathology reporting/documentation

Summary Table 62. Pathology reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Reporting having performed flow cytometry (microscopic) ^ IV ^
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 95.3%/NA
Reporting cytometry ploidy (microscopic) ^ IV ^
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 98.9%/NA
Pathology reports on chart ^ IV ^
Shank, 2000, US | Random sample women stage I–II invasive BC treated in 1993-1994 | 727 | 1995-1996 | 99.7%/NA

Summary Table 63. Imaging reporting/documentation

Summary Table 63. Imaging reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Size of mammographic abnormality ^ IV ^
White, 2003, US | Convenience sample women BC stage I–II diagnosed in 1994 | 16,643 | 1994 | 47%/Age: <70 y: 45.9%; ≥70 y: 50.7%/Race: White: 47.5%; Black-Hispanic: 46.3%/Payer: Government: 50.3%; Private: 44.8% S

KEY: Key differences = regarding age, race, ethnicity, or SES; SES = socioeconomic status; NA = not assessed; BC = breast cancer; NR = not reported; DCIS = ductal carcinoma in situ; S = significant; NS = nonsignificant; Mx = mammography; H = Hispanic; Bx = biopsy; ALND = axillary lymph node dissection; TNM = tumor;node;metastasis state; Level Ia = pre-study data indicating consistently sound psychometric properties; Iac = pre- and on-study data indicating consistently sound psychometric properties; IV = no pre- or on-study psychometric data

Summary Table 64. Chemotherapy reporting/documentation

Summary Table 64. Chemotherapy reporting/documentation

Author, Year, Location | Sample description | No. Eligible | Measurement Period | Rate (%)/ Key differences
Presence of chemotherapy flow sheets in active treatment charts ^ IV ^
Cornfeld, 2001, US | Convenience sample women BC treated in the private practice of 11 oncologists | 220 | 1999-2000 (9 mo) | 99%/NA
Presence of body surface area calculations on chemotherapy flow sheets ^ IV ^
Cornfeld, 2001, US | Convenience sample women BC treated in the private practice of 11 oncologists | 220 | 1999-2000 (9 mo) | 90%/NA

KEY: Key differences = regarding age, race, ethnicity, or SES; SES = socioeconomic status; NA = not assessed; BC = breast cancer; NR = not reported; DCIS = ductal carcinoma in situ; S = significant; NS = nonsignificant; Mx = mammography; H = Hispanic; Bx = biopsy; ALND = axillary lymph node dissection; TNM = tumor;node;metastasis state; Level Ia = pre-study data indicating consistently sound psychometric properties; Iac = pre- and on-study data indicating consistently sound psychometric properties; IV = no pre- or on-study psychometric data