# References and Included Studies

1 Institute of Medicine. Committee on the National Quality Report on Health Care Delivery. Envisioning the National Health Care Quality Report. Washington, D.C.: National Academy Press, 2001.
2 McGlynn E A. Introduction and overview of the conceptual framework for a national quality measurement and reporting system. Med Care. 2003;41(1 Suppl):I1-7. [pmid: 12719686].
3 Chassin M R, Galvin R W. The urgent need to improve health care quality. Institute of Medicine National Roundtable on Health Care Quality. JAMA. 1998;280(11):1000-5. [pmid: 9749483].
4 Committee on the Quality of Health Care in America, Institute of Medicine. Crossing the quality chasm: a new health system for the 21st century. Washington, DC: National Academy Press, 2001.
5 McGlynn E A, Asch S M, Adams J, et al. The quality of health care delivered to adults in the United States. N Engl J Med. 2003;348(26):2635-45. [pmid: 12826639].
6 Kahn K L, Malin J L, Adams J, et al. Developing a reliable, valid, and feasible plan for quality-of-care measurement for cancer: how should we measure?. Med Care. 2002;40(6 Suppl):III73-85. [pmid: 12064761].
7 Solberg L I, Mosser G, McDonald S. The three faces of performance measurement: improvement, accountability, and research. Jt Comm J Qual Improv. 1997;23(3):135-47. [pmid: 9103968].
8 Agency for Healthcare Research and Quality. National Quality Measures Clearinghouse. 2003. Available at: http://www.qualitymeasures.ahrq.gov/resources/measure_use Accessed April 2, 2003.
9 The National Roundtable on Health Care Quality, Division of Health Care Services, Institute of Medicine. Measuring the quality of health care. National Academy Press, 1999.
10 Schneider E C, Zaslavsky A M, Epstein A M. Racial disparities in the quality of care for enrollees in medicare managed care. JAMA. 2002;287(10):1288-94. [pmid: 11886320].
11 Malin J L, Asch S M, Kerr E A, et al. Evaluating the quality of cancer care: development of cancer quality indicators for a global quality assessment tool. Cancer. 2000;88(3):701-7. [pmid: 10649266].
12 McGlynn E A. Selecting common measures of quality and system performance. Med Care. 2003;41(1 Suppl):I39-47. [pmid: 12719686].
13 Sauerland S, Neugebauer E. Consensus conferences must include a systematic search and categorization of the evidence. Surg Endosc. 2000;14(10):908-10. [pmid: 11080401].
14 McGlynn E A, Kerr E A, Asch S M. New approach to assessing clinical quality of care for women: the QA Tool system. Womens Health Issues. 1999;9(4):184-92. [pmid: 10405590].
15 McGlynn E A. Choosing and evaluating clinical performance measures. Jt Comm J Qual Improv. 1998;24(9):470-9. [pmid: 9770637].
16 Brook RH. The RAND/UCLA appropriateness method. In: McCormick KA, Moore SR, Siegel RA, editors. Clinical practice guideline development: methodology perspectives. Rockville, MD: Agency for Health Care Policy and Research (AHCPR publication no. 95-0009); 1994, p.59–70.
17 Asch SM, Kerr EA, Hamilton EG, et al. Quality of care for oncologic conditions and HIV: a review of the literature and quality indicators. Santa Monica, CA: RAND, 2000.
18 Streiner DL, Norman GR. Health measurement scales. A practical guide to their development and use. 2 ed. New York: Oxford University Press, 2000.
19 Center for Health Policy Studies, Harvard School of Public Health Center for Quality of Care Research and Education. Understanding and choosing clinical performance measures for quality improvement: development of typology. Final report. Rockville, MD: Agency for Healthcare Research and Quality (AHRQ), 1995.
20 Lawthers AW, Palmer H. In search of a few good performance measures. In: Seltzer J, Nash DB, editors. Models for measuring quality in managed care: analysis and impact. New York, NY: Faulkner and Gray's Healthcare Information Center, 1997.
21 Institute of Medicine. Clinical Practice Guidelines: Directions for a new program. Washington, DC: National Academy Press, 1990.
22 Rubin H R, Pronovost P, Diette G B. The advantages and disadvantages of process-based measures of health care quality. Int J Qual Health Care. 2001;13(6):469-74. [pmid: 11769752].
23 President's Advisory Commission on Consumer Protection and Quality in the Health Care Industry. Quality first: better health care for all Americans. 1998.
24 Berwick D M, James B, Coye M J. Connections between quality measurement and improvement. Med Care. 2003;41(1 Suppl):I30-8. [pmid: 12544814].
25 James B. Information system concepts for quality measurement. Med Care. 2003;41(1 Suppl):I71-9. [pmid: 12544818].
26 Cancer facts and figures 2003. American Cancer Society, 2003. Available at: www.cancer.org.
27 SEER Cancer Statistics Review, 1975-2000. Bethesda, MD: National Cancer Institute, 2003.
28 Pruthi S. Detection and evaluation of a palpable breast mass. Mayo Clin Proc. 2001;76(6):641-7. [pmid: 11702901].
29 Donegan W L. Evaluation of a palpable breast mass. N Engl J Med. 1992;327(13):937-42. [pmid: 1513351].
30 Kerlikowske K, Smith-Bindman R, Ljung B M, et al. Evaluation of abnormal mammography results and palpable breast abnormalities. Ann Intern Med. 2003;139(4):274-84. [pmid: 12965983].
31 Ciatto S, Bravetti P, Bonardi R, et al. The role of mammography in women under 30. Radiol Med (Torino). 1990;80(5):676-8. [pmid: 2267387].
32 Flobbe K, Nelemans P J, Kessels A G, et al. The role of ultrasonography as an adjunct to mammography in the detection of breast cancer. a systematic review. Eur J Cancer. 2002;38(8):1044-50. [pmid: 12008191].
33 Mehta T S. Current uses of ultrasound in the evaluation of the breast. Radiol Clin North Am. 2003;41(4):841-56. [pmid: 12899495].
34 Schnall M D. Breast MR imaging. Radiol Clin North Am. 2003;41(1):43-50. [pmid: 12630684].
35 Rose C, Dose J, Avril N. Positron emission tomography for the diagnosis of breast cancer. Nucl Med Commun. 2002;23(7):613-8. [pmid: 12089482].
36 Cheung K L, Graves C R, Robertson J F. Tumour marker measurements in the diagnosis and monitoring of breast cancer. Cancer Treat Rev. 2000;26(2):91-102. [pmid: 10772967].
37 Miki Y, Swensen J, Shattuck-Eidens D, et al. A strong candidate for the breast and ovarian cancer susceptibility gene BRCA1. Science. 1994;266(5182):66-71. [pmid: 7939630].
38 Wooster R, Neuhausen S L, Mangion J, et al. Localization of a breast cancer susceptibility gene, BRCA2, to chromosome 13q12–13. Science. 1994;265(5181):2088-90. [pmid: 8091231].
39 Mincey B A. Genetics and the management of women at high risk for breast cancer. Oncologist. 2003;8(5):466-73. [pmid: 14530500].
40 Rastogi P, Vogel V G. Update on breast cancer prevention. Oncology (Huntingt). 2003;17(6):799-805. [pmid: 12846124].
41 Singletary S E, Greene F L. Revision of breast cancer staging: the 6th edition of the TNM Classification. Semin Surg Oncol. 2003;21(1):53-9. [pmid: 12923916].
42 Wilcken N, Hornbuckle J, Ghersi D. Chemotherapy alone versus endocrine therapy alone for metastatic breast cancer. Cochrane Database Syst Rev 2003;(2):CD002747.
43 Veronesi U, Cascinelli N, Mariani L, et al. Twenty-year follow-up of a randomized study comparing breast-conserving surgery with radical mastectomy for early breast cancer. N Engl J Med. 2002;347(16):1227-32. [pmid: 12393819].
44 Veronesi U, Paganelli G, Viale G, et al. A randomized comparison of sentinel-node biopsy with routine axillary dissection in breast cancer. N Engl J Med. 2003;349(6):546-53. [pmid: 12904519].
45 Radiotherapy for early breast cancer. Cochrane Database Syst Rev 2002;(2):CD003647.
46 Favourable and unfavourable effects on long-term survival of radiotherapy for early breast cancer: an overview of the randomised trials. Early Breast Cancer Trialists' Collaborative Group. Lancet 2000;355(9217):1757–70.
47 Nag S, Kuske RR, Vicini FA, et al. Brachytherapy in the treatment of breast cancer. Oncology (Huntingt) 2001;15(2):195–202, 205.
48 Veronesi U, Galimberti V, Zurrida S, et al. Sentinel lymph node biopsy as an indicator for axillary dissection in early breast cancer. Eur J Cancer. 2001;37(4):454-58. [pmid: 11267853].
49 Aapro M S. Adjuvant therapy of primary breast cancer: a review of key findings from the 7th international conference, St. Gallen, February 2001. Oncologist. 2001;6(4):376-85. [pmid: 11524557].
50 Goldhirsch A, Wood W C, Gelber R D, et al. Meeting highlights: updated international expert consensus on the primary therapy of early breast cancer. J Clin Oncol. 2003;21(17):3357-65. [pmid: 12847142].
51 Gradishar W J. Adjuvant systemic therapy of early stage breast cancer. Curr Treat Options Oncol. 2003;4(2):141-50. [pmid: 12594940].
52 Henderson I C, Berry D A, Demetri G D, et al. Improved outcomes from adding sequential Paclitaxel but not from escalating Doxorubicin dose in an adjuvant chemotherapy regimen for patients with node-positive primary breast cancer. J Clin Oncol. 2003;21(6):976-83. [pmid: 12637460].
53 Mamounas EP, Bryant J, Lembersky BC, et al. Paclitaxel (T) following doxorubicin/cyclophosphamide (AC) as adjuvant chemotherapy for node-positive breast cancer: Results from NSABP B-28. Proc Am Soc Clin Oncol 22[4(abstract 12)]. 2003.
54 Ghersi D, Wilcken N, Simes J, et al. Taxane containing regimens for metastatic breast cancer. Cochrane Database Syst Rev 2003;(1):CD003366.
55 Kelleher M, Miles D. 21. The adjuvant treatment of breast cancer. Int J Clin Pract. 2003;57(3):195-9. [pmid: 12723723].
56 Fisher B, Dignam J, Bryant J, et al. Five versus more than five years of tamoxifen for lymph node-negative breast cancer: updated findings from the National Surgical Adjuvant Breast and Bowel Project B-14 randomized trial. J Natl Cancer Inst. 2001;93(9):684-90. [pmid: 11333290].
57 Abrams J S. Tamoxifen: five versus ten years--is the end in sight?. J Natl Cancer Inst. 2001;93(9):662-4. [pmid: 11333277].
58 Stewart H J, Prescott R J, Forrest A P. Scottish adjuvant tamoxifen trial: a randomized study updated to 15 years. J Natl Cancer Inst. 2001;93(6):456-62. [pmid: 11259471].
59 Early Breast Cancer Trialists' Collaborative Group. Tamoxifen for early breast cancer. [Review][31 refs]. Cochrane Database Syst Rev 2001;(1):CD000486.
60 Early Breast Cancer Trialists' Collaborative Group. Ovarian ablation for early breast cancer.[update of Cochrane Database Syst Rev. 2000;(2):CD000485]. [Review][19 refs]. Cochrane Database Syst Rev 2000;(3):CD000485.
61 Smith I E, Dowsett M. Aromatase inhibitors in breast cancer. N Engl J Med. 2003;348(24):2431-42. [pmid: 12802030].
62 Baum M, Budzar A U, Cuzick J, et al. Anastrozole alone or in combination with tamoxifen versus tamoxifen alone for adjuvant treatment of postmenopausal women with early breast cancer: first results of the ATAC randomised trial. Lancet. 2002;359(9324):2131-9. [pmid: 12090977].
63 Ravdin P. Aromatase inhibitors for the endocrine adjuvant treatment of breast cancer. Lancet. 2002;359(9324):2126-7. [pmid: 12090973].
64 Goss P E, Ingle J N, Martino S, et al. A randomized trial of letrozole in postmenopausal women after five years of tamoxifen therapy for early-stage breast cancer. N Engl J Med. 2003;349(19):1793-1802. [pmid: 14551341].
65 Bryant J, Wolmark N. Letrozole after tamoxifen for breast cancer--what is the price of success?. N Engl J Med. 2003;349(19):1855-7. [pmid: 14551339].
66 Slamon D J, Leyland-Jones B, Shak S, et al. Use of chemotherapy plus a monoclonal antibody against HER2 for metastatic breast cancer that overexpresses HER2. N Engl J Med. 2001;344(11):783-92. [pmid: 11248153].
67 Vogel C L, Cobleigh M A, Tripathy D, et al. Efficacy and safety of trastuzumab as a single agent in first-line treatment of HER2-overexpressing metastatic breast cancer. J Clin Oncol. 2002;20(3):719-26. [pmid: 11821453].
68 Slamon D J, Godolphin W, Jones L A, et al. Studies of the HER-2/neu proto-oncogene in human breast and ovarian cancer. Science. 1989;244(4905):707-12. [pmid: 2470152].
69 Klijn J G, Blamey R W, Boccardo F, et al. Combined tamoxifen and luteinizing hormone-releasing hormone (LHRH) agonist versus LHRH agonist alone in premenopausal advanced breast cancer: a meta-analysis of four randomized trials.[comment]. J Clin Oncol. 2001;19(2):343-53. [pmid: 11208825].
70 Campos S M, Winer E P. Hormonal therapy in postmenopausal women with breast cancer. Oncology. 2003;64(4):289-99. [pmid: 12759523].
71 Dixon J M, Anderson T J, Miller W R. Neoadjuvant endocrine therapy of breast cancer: a surgical perspective. Eur J Cancer. 2002;38(17):2214-21. [pmid: 12441257].
72 Wolff A C, Davidson N E. Primary systemic therapy in operable breast cancer. J Clin Oncol. 2000;18(7):1558-69. [pmid: 10735905].
73 Bear H D, Anderson S, Brown A, et al. The effect on tumor response of adding sequential preoperative docetaxel to preoperative doxorubicin and cyclophosphamide: preliminary results from National Surgical Adjuvant Breast and Bowel Project Protocol B-27. J Clin Oncol. 2003;21(22):4165-74. [pmid: 14559892].
74 Sakorafas G H, Tsiotou A G, Pavlakis G. Follow-up after primary treatment for breast cancer. [Review] [52 refs]. Acta Oncol. 2000;39(8):935-40. [pmid: 11207000].
75 Emens L A, Davidson N E. The follow-up of breast cancer. [Review] [67 refs]. Semin Oncol. 2003;30(3):338-48. [pmid: 12870135].
76 American Society of Clinical Oncology (ASCO). ASCO patient guide: follow-up care for breast cancer. 2001.
77 Melville A, Haward B. Producing evidence-based guidance on cancer services: challenges and lessons [abstract]. Annual Meeting of International Society of Technology Assessment in Health Care. 1997;13:93.
78 Ganz P A, Desmond K A, Leedham B, et al. Quality of life in long-term, disease-free survivors of breast cancer: a follow-up study. J Natl Cancer Inst. 2002;94(1):39-49. [pmid: 11773281].
79 Thorne S, Balneaves L, Reimer J. Practical support for women with breast cancer. Can Oncol Nurs J 1999;9(2):74–7,-82–5.
80 Rosenbaum EH, Rosenbaum I. Supportive Cancer Care. Naperville, IL: Sourcebooks Inc, 2001.
81 Ferrell B R, Grant M M, Funk B M, et al. Quality of life in breast cancer survivors: implications for developing support services. Oncol Nurs Forum. 1998;25(5):887-95. [pmid: 9644705].
82 Davies M, Sque M. Living on the outside looking in: a theory of living with advanced breast cancer. Int J Palliat Nurs. 2002;8(12):583-90. [pmid: 12560800].
83 Graham I D, Harrison M B, Brouwers M, et al. Facilitating the use of evidence in practice: evaluating and adapting clinical practice guidelines for local use by health care organizations. J Obstet Gynecol Neonatal Nurs. 2002;31(5):599-611. [pmid: 12353740].
84 AGREE Collaboration. Appraisal of guidelines for research and evaluation. 2003.
85 Shekelle P G, Ortiz E, Rhodes S, et al. Validity of the Agency for Healthcare Research and Quality clinical practice guidelines: how quickly do guidelines become outdated?. JAMA. 2001;286(12):1461-7. [pmid: 11572738].
86 Moher D, Cook D J, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-1900. [pmid: 10584742].
87 Bossuyt P M, Reitsma J B, Bruns D E, et al. The STARD statement for reporting studies of diagnostic accuracy: explanation and elaboration. Ann Intern Med. 2003;138(1):W1-12. [pmid: 12513067].
88 Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
89 Schulz K F. Subverting randomization in controlled trials. JAMA. 1995;274(18):1456-8. [pmid: 7474192].
90 McGlynn E A. An evidence-based national quality measurement and reporting system. Med Care. 2003;41(1 Suppl):I8-15. [pmid: 12719686].
91 National Library of Medicine. Search strategy used to create the systematic reviews subset on PubMed (last modified March 2003). 2003.
92 Berlin J A. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350(9072):185-6. [pmid: 9250191].
93 Cunningham R. Perspectives. Indefinite results in ABMT (autologous bone marrow transplantation) trials add to challenges for practice standards, quality assurance in cancer care. Medicine & Health 1999;53(16):suppl 1–4.
94 Breast care services: results of ECRI benchmarking study. Executive Briefings; no. 56. Plymouth Meeting, PA: ECRI, 1997; 10 p.
95 Saeki T. What is the Japanese consensus on adjuvant chemotherapy in breast cancer?. Breast Cancer. 2003;10(1):15-20. [pmid: 14634511].
96 Roila F B. Adjuvant systemic therapies in women with breast cancer: an audit of clinical practice in Italy. Ann Oncol. 2003;14(6):843-8. [pmid: 12796020].
97 Meijer W S. [Follow-up after oncological surgery].[comment]. [Dutch]. Ned Tijdschr Geneeskd. 2002;146(4):186-7. [pmid: 12532672].
98 Recht A, Edge S B, Solin L J, et al. Postmastectomy radiotherapy: clinical practice guidelines of the American Society of Clinical Oncology. J Clin Oncol. 2001;19(5):1539-69. [pmid: 11230499].
99 Hillner B E, Smith T J, Desch C E. Hospital and physician volume or specialization and outcomes in cancer treatment: importance in quality of cancer care. [Review] [69 refs]. J Clin Oncol. 2000;18(11):2327-40. [pmid: 10829054].
100 Schwartz G F, Solin L J, Olivotto I A, et al. The Consensus Conference on the treatment of in situ ductal carcinoma of the breast, April 22–25, 1999. [Review] [3 refs]. Hum Pathol. 2000;31(2):131-9. [pmid: 10685626].
101 Duigou F, Herlin P, Marnay J, et al. Variation of flow cytometric DNA measurement in 1,485 primary breast carcinomas according to guidelines for DNA histogram interpretation. Cytometry. 2000;42(1):35-42. [pmid: 10679741].
102 Bland K I, Scott-Conner C E, Menck H, et al. Axillary dissection in breast-conserving surgery for stage I and II breast cancer: a National Cancer Data Base study of patterns of omission and implications for survival. J Am Coll Surg. 1999;188(6):586-95. [pmid: 10359351].
103 Lyman G, Djulbegovic B. Review and Evaluation of Clinical Practice Guidelines in Oncology. (Meeting abstract). 1998.
104 Health care guideline: breast cancer treatment. In: Institute for Clinical Systems Integration 1996 health care guidelines, Volume 1 1996; Bloomington, MN:ICSI-52.
105 Parvanova V. [Modern indications for postmastectomy radiotherapy application]. [Bulgarian]. Rentgenologiya i Radiologiya. 2002;41(4):275-80.
106 Roumen R M H, Pijpers H J, Thunnissen F B J M, et al. [Summary of the guideline ‘sentinel node biopsy in breast cancer’]. [Dutch]. Ned Tijdschr Geneeskd. 2000;144(39):1864-7. [pmid: 11031679].
107 Nattinger A B, Gottlieb M S, Hoffman R G, et al. Minimal increase in use of breast-conserving surgery from 1986 to 1990. Med Care. 1996;34(5):479-89. [pmid: 8614169].
108 Berner A S. [Fine-needle aspiration cytology or core biopsy when diagnosing tumours of the breast.]. Tidsskr Nor Laegeforen. 2003;123(12):1677-9. [pmid: 12821988].
109 Appleton M A, Douglas-Jones A G, Morgan J M. Evidence of effectiveness of clinical audit in improving histopathology reporting standards of mastectomy specimens. J Clin Pathol. 1998;51(1):30-3. [pmid: 9577368]. [pmcid: 500427].
110 Bernhard J, Hurny C, Coates AS, et al. Quality of life assessment in patients receiving adjuvant therapy for breast cancer: the IBCSG approach. The International Breast Cancer Study Group. [erratum appears in Ann Oncol 1998 Feb;9(2):231]. Ann Oncol 1997;8(9):825–35.
111 Bickell N A, Aufses A H Jr, Chassin M R. The quality of early-stage breast cancer care. Ann Surg. 2000;232(2):220-4. [pmid: 10903601]. [pmcid: 1421134].
112 Bickell N A, McEvoy M D. Physicians' reasons for failing to deliver effective breast cancer care: a framework for underuse. [comment]. Med Care. 2003;41(3):442-6. [pmid: 12618647].
113 Bower J E, Ganz P A, Desmond K A, et al. Fatigue in breast cancer survivors: occurrence, correlates, and impact on quality of life. J Clin Oncol. 2000;18(4):743-53. [pmid: 10673515].
114 Brenin D R, Morrow M, Moughan J, et al. Management of axillary lymph nodes in breast cancer: a national patterns of care study of 17,151 patients. Ann Surg. 1999;230(5):686-91. [pmid: 10561093]. [pmcid: 1420923].
115 Northouse L L, Caffey M, Deichelbohrer L, et al. The quality of life of African American women with breast cancer. Res Nurs Health. 1999;22(6):449-60. [pmid: 10630287].
116 Cheung K L. Management of primary breast cancer in Hong Kong -- can the guidelines be met?. Eur J Surg Oncol. 1999;25(3):255-60. [pmid: 10336803].
117 Chie W C, Huang C S, Chen J H, et al. Measurement of the quality of life during different clinical phases of breast cancer. J Formos Med Assoc. 1999;98(4):254-60. [pmid: 10389369].
118 Christensen L B, Rank F E, Blichert-Toft M, et al. [Mammographic screening in the municipality of Copenhagen 1991-1997. Evaluation of the preoperative assessment]. [Danish]. Ugeskr Laeger. 2002;164(2):191-5. [pmid: 11831088].
119 Cochrane R A, Singhal H, Monypenny I J, et al. Evaluation of general practitioner referrals to a specialist breast clinic according to the UK national guidelines. Eur J Surg Oncol. 1997;23(3):198-201. [pmid: 9236889].
120 Cornfeld M J, Jadwin A, O'Grady P, et al. Feasibility of assessing quality in medical oncology practices. Cancer Pract. 2001;9(5):231-5. [pmid: 11879319].
121 Craft P S, Zhang Y, Brogan J, et al. Implementing clinical practice guidelines: a community-based audit of breast cancer treatment. Australian Capital Territory and South Eastern New South Wales Breast Cancer Treatment Group. [comment]. Med J Aust. 2000;172(5):213-6. [pmid: 10776392].
122 DeMichele A, Putt M, Zhang Y, et al. Older age predicts a decline in adjuvant chemotherapy recommendations for patients with breast carcinoma: evidence from a tertiary care cohort of chemotherapy-eligible patients. Cancer. 2003;97(9):2150-9. [pmid: 12712466].
123 Dow K H, Lafferty P. Quality of life, survivorship, and psychosocial adjustment of young women with breast cancer after breast-conserving surgery and radiation therapy. Oncol Nurs Forum. 2000;27:1555-64. [pmid: 11103374].
124 Du X, Goodwin J S. Increase of chemotherapy use in older women with breast carcinoma from 1991 to 1996. Cancer. 2001;92(4):730-7. [pmid: 11550141].
125 Du XL, Key CR, Osborne C, et al. Discrepancy between consensus recommendations and actual community use of adjuvant chemotherapy in women with breast cancer.[summary for patients in Ann Intern Med. 2003 Jan 21;138(2):I16; PMID: 12529113]. Ann Intern Med 2003;138(2):90–7.
126 Edge S B, Gold K, Berg C D, et al. Patient and provider characteristics that affect the use of axillary dissection in older women with stage I–II breast carcinoma. Cancer. 2002;94(10):2534-41. [pmid: 12173318].
127 Engel J, Nagel G, Breuer E, et al. Primary breast cancer therapy in six regions of Germany. Eur J Cancer. 2002;38(4):578-85. [pmid: 11872353].
128 Foroudi F, Tyldesley S, Walker H, et al. An evidence-based estimate of appropriate radiotherapy utilization rate for breast cancer. Int J Radiat Oncol Biol Phys. 2002;3(5):1240-53. [pmid: 12128126].
129 Frazer G H, Brown C H III, Graves T K. A longitudinal outcome assessment of quality of life indicators among selected cancer patients. J Rehabil Outcomes Measure. 1998;2(2):40-7.
130 Guadagnoli E, Shapiro C, Gurwitz J H, et al. Age-related patterns of care: evidence against ageism in the treatment of early-stage breast cancer. J Clin Oncol. 1997;15(6):2338-44. [pmid: 9196148].
131 Guadagnoli E, Shapiro C L, Weeks J C, et al. The quality of care for treatment of early stage breast carcinoma: is it consistent with national guidelines?. Cancer. 1998;83(2):302-9. [pmid: 9669813].
132 Guadagnoli E, Weeks J C, Shapiro C L, et al. Use of breast-conserving surgery for treatment of stage I and stage II breast cancer. J Clin Oncol. 1998;16(1):101-6. [pmid: 9440729].
133 Haas J S, Cook E F, Puopolo A L, et al. Differences in the quality of care for women with an abnormal mammogram or breast complaint.[comment]. J Gen Intern Med. 2000;15(5):321-8. [pmid: 10840267]. [pmcid: 1495454].
134 Harlan L C, Abrams J, Warren J L, et al. Adjuvant therapy for breast cancer: practice patterns of community physicians. J Clin Oncol. 2002;20(7):1809-17. [pmid: 11919238].
135 Hebert-Croteau N, Brisson J, Latreille J, et al. Compliance with consensus recommendations for the treatment of early stage breast carcinoma in elderly women. Cancer. 1999;85(5):1104-13. [pmid: 10091795].
136 Hislop T G, Coldman A J, Olivotto I A, et al. Local and regional therapy for women with breast cancer in British Columbia. Breast J. 2003;9(3):192-9. [pmid: 12752627].
137 Imperato P J, Waisman J, Wallen M, et al. Breast cancer pathology practices among Medicare patients undergoing unilateral extended simple mastectomy. J Womens Health Gend Based Med. 2002;11(6):537-47. [pmid: 12225627].
138 Jackson S M, Baerg B. Compliance with radiation treatment guidelines in a provincial setting. Cancer Prev Control. 1999;3(3):196-201. [pmid: 10474767].
139 Jansen S J, Stiggelbout A M, Nooij M A, et al. Response shift in quality of life measurement in early-stage breast cancer patients undergoing radiotherapy. Qual Life Res. 2000;9(6):603-15. [pmid: 11236851].
140 Keating N L, Weeks J C, Landrum M B, et al. Discussion of treatment options for early-stage breast cancer: effect of provider specialty on type of surgery and satisfaction. Med Care. 2001;39(7):681-91. [pmid: 11458133].
141 Khawaja A R, Allan S M. Audit of referral practice to a fast-access breast clinic before the guaranteed 2-week wait. Ann R Coll Surg Engl. 2001;83(1):58-60. [pmid: 11212454].
142 Lazovich D, White E, Thomas D B, et al. Change in the use of breast-conserving surgery in western Washington after the 1990 NIH Consensus Development Conference. Arch Surg. 1997;132(4):418-23. [pmid: 9108764].
143 Lazovich D, Solomon C C, Thomas D B, et al. Breast conservation therapy in the United States following the 1990 National Institutes of Health Consensus Development Conference on the treatment of patients with early stage invasive breast carcinoma. Cancer. 1999;86(4):628-37. [pmid: 10440690].
144 Legorreta A P, Liu X, Parker R G. Examining the use of breast-conserving treatment for women with breast cancer in a managed care environment. Am J Clin Oncol. 2000;23(5):438-41. [pmid: 11039500].
145 Mandelblatt J S, Berg C D, Meropol N J, et al. Measuring and predicting surgeons' practice styles for breast cancer treatment in older women. Med Care. 2001;39(3):228-42. [pmid: 11242318].
146 Mandelblatt J S, Kerner J F, Hadley J, et al. Variations in breast carcinoma treatment in older medicare beneficiaries: is it black or white. Cancer. 2002;95(7):1401-14. [pmid: 12237908].
147 McCarthy D O, Blamey R W, Robertson J F, et al. A one-year audit of 255 operable breast cancers. Eur J Surg Oncol. 1997;23(5):399-402. [pmid: 9393566].
148 Molenaar S, Sprangers M A, Rutgers E J, et al. Decision support for patients with early-stage breast cancer: effects of an interactive breast cancer CDROM on treatment decision, satisfaction, and quality of life. J Clin Oncol. 2001;19(6):1676-87. [pmid: 11250997].
149 Mor V, Malin M, Allen S. Age differences in the psychosocial problems encountered by breast cancer patients. J Natl Cancer Inst Monogr 1994;(16):191–7.
150 Mor V, Laliberte L L, Petrisek A C, et al. Impact of breast cancer treatment guidelines on surgeon practice patterns: results of a hospital-based intervention. Surgery. 2000;128(5):847-61. [pmid: 11056451].
151 Morrow M, White J, Moughan J, et al. Factors predicting the use of breast-conserving therapy in stage I and II breast carcinoma. [comment]. J Clin Oncol. 2001;19(8):2254-62. [pmid: 11304779].
152 Nattinger A B, Hoffmann R G, Kneusel R T, et al. Relation between appropriateness of primary therapy for early-stage breast carcinoma and increased use of breast-conserving surgery. [comment]. Lancet. 2000;356(9236):1148-53. [pmid: 11030294].
153 Osoba D, Burchmore M. Health-related quality of life in women with metastatic breast cancer treated with trastuzumab (Herceptin). Semin Oncol. 1999;26(4 Suppl 12):84-8. [pmid: 10482198].
154 Ottevanger P B, De Mulder P H, Grol R P, et al. Effects of quality of treatment on prognosis in primary breast cancer patients treated in daily practice. Anticancer Res. 2002;22(1A):459-65. [pmid: 12017333].
155 Palazzi M, De Tomasi D, D'Affronto C, et al. Are international guidelines for the prescription of adjuvant treatment for early breast cancer followed in clinical practice? Results of a population-based study on 1547 patients. Tumori. 2002;88(6):503-6. [pmid: 12597147].
156 Perez D J, Williams S M, Christensen E A, et al. A longitudinal study of health related quality of life and utility measures in patients with advanced breast cancer. Qual Life Res. 2001;10:587-93. [pmid: 11822792].
157 Ray-Coquard I, Philip T, Lehmann M, et al. Impact of a clinical guidelines program on medical practice in a French cancer center (Meeting abstract). J Clin Oncol 1997;16.
158 Ray-Coquard I, Philip T, Lehmann M, et al. Impact of a clinical guidelines program for breast and colon cancer in a French cancer center. JAMA. 1997;278(19):1591-5. [pmid: 9370505].
159 Ray-Coquard I, Philip T, de Laroche G, et al. A controlled “before-after” study: impact of a clinical guidelines programme and regional cancer network organization on medical practice. Br J Cancer. 2002;86(3):313-21. [pmid: 11875690].
160 Sauven P, Bishop H, Patnick J, et al. The National Health Service Breast Screening Programme and British Association of Surgical Oncology audit of quality assurance in breast screening 1996-2001. Br J Surg. 2003;90(1):82-7. [pmid: 12520580].
161 Sawka C, Olivotto I, Coldman A, et al. The association between population-based treatment guidelines and adjuvant therapy for node-negative breast cancer. British Columbia/Ontario Working Group. Br J Cancer. 1997;75(10):1534-42. [pmid: 9166950].
162 Shank B, Moughan J, Owen J, et al. The 1993-94 patterns of care process survey for breast irradiation after breast-conserving surgery-comparison with the 1992 standard for breast conservation treatment. The Patterns of Care Study, American College of Radiology. Int J Radiat Oncol Biol Phys. 2000;48(5):1291-9. [pmid: 11121625].
163 Silliman R A, Demissie S, Troyan S L. The care of older women with early-stage breast cancer: what is the role of surgeon gender?. Med Care. 1999;37(10):1057-67. [pmid: 10524372].
164 Solin L J, Schultz D J, Hanchak N A, et al. Patterns of treatment for older women with newly diagnosed breast carcinoma. Am J Clin Oncol. 1999;22(2):107-13. [pmid: 10199441].
165 Tyldesley S, Foroudi F, Barbera L, et al. The appropriate rate of breast conserving surgery: an evidence-based estimate. Clin Oncol (R Coll Radiol). 2003;15(3):144-55. [pmid: 12801054].
166 White J, Morrow M, Moughan J, et al. Compliance with breast-conservation standards for patients with early-stage breast carcinoma. Cancer. 2003;97(4):893-904. [pmid: 12569588].
167 Wilkinson N W, Shahryarinejad A, Winston J S, et al. Concordance with breast cancer pathology reporting practice guidelines.[comment]. J Am Coll Surg. 2003;196(1):38-43. [pmid: 12517547].
168 Nagel G, Rohrig B, Hoyer H, et al. [A population-based study on variations in the use of adjuvant radiotherapy in breast cancer patients]. [German]. Strahlenther Onkol. 2002;178(11):589-96. [pmid: 12426669].
169 Dillman R O, Chico S. Radiologic tests after a new diagnosis of breast cancer. Eff Clin Pract. 2000;3(1):1-6. [pmid: 10788031].
170 Malin J L, Schuster M A, Kahn K A, et al. Quality of breast cancer care: what do we know?.[Review] [87 refs]. J Clin Oncol. 2002;20(21):4381-93. [pmid: 12409338].
171 Malin J L, Asch S M, Kerr E A, et al. Evaluating the quality of cancer care: development of cancer quality indicators for a global quality assessment tool. Cancer. 2000;88(3):701-7. [pmid: 10649266].
172 McGlynn E A, Kerr E A, Adams J, et al. Quality of health care for women: a demonstration of the quality assessment tools system. Med Care. 2003;41(5):616-25. [pmid: 12719686].
173 American Cancer Society. American Cancer Society estimates for 1996. Based on projected resident population of the United States. Washington, DC: US Bureau of the Census, 1996.
174 McGlynn E A, Brook R H. Keeping quality on the policy agenda. Health Aff (Millwood). 2001;20(3):82-90. [pmid: 11585185].
175 Galvin R S, McGlynn E A. Using performance measurement to drive improvement: a road map for change. Med Care. 2003;41(1 Suppl):I48-60. [pmid: 12544816].
176 Leatherman S T, Hibbard J H, McGlynn E A. A research agenda to advance quality measurement and improvement. Med Care. 2003;41(1 Suppl):I80-6. [pmid: 12544819].
177 Hibbard J H. Engaging health care consumers to improve the quality of care. Med Care. 2003;41(1 Suppl):I61-70. [pmid: 12544819].