# Acknowledgments

The authors would like to thank several individuals for their support of the present project: Isabella Steffensen and Christine Murray for their ability to help us say what we mean and mean what we say; Jennifer Malin for her guidance very early on in the process; Mark Somerfield at the American Society of Clinical Oncology (ASCO) for trying to facilitate access to ASCO's quality measures currently being tested in the field; Guenter Ollenschlaeger of the Guidelines International Network for his enthusiasm and support for the since-dropped, expanded scope of the review; Isabelle French for coordinating our review team particularly in early interactions with our TEP; Steve Clauser, Molla Donaldson, and Joe Lipscomb (National Cancer Institute), Nancy Lee and Mary White (Centers for Disease Control and Prevention), and Judy Goldfarb (Centers for Medicare and Medicaid Services), who shared the Federal Partners' vision at the outset; Rosaly Correa-de-Araujo for her ideas at the initiation of the project; and, Stacie Jones of the Agency for Healthcare Quality and Research for her untiring efforts, as our Task Order (i.e., Project) Officer, to make the process as fruitful and enjoyable as possible.