# Appendix I. Additional Acknowledgments

## The UO-EPC gratefully acknowledges the following individuals who served on our Technical Expert Panel (TEP). Acknowledgment does not reflect endorsement of this report

- James L. Connolly MD
- Professor of Pathology
- Harvard Medical School
- Boston, MA

- Mark N. Levine MD
- Buffett Taylor Chair in Breast Cancer Research
- McMaster University
- Hamilton, ON

- Elizabeth A. McGlynn PhD, MPP, BA
- Director
- Center for Research on Quality in Health Care RAND
- Santa Monica, CA

- Dr. Maureen Trudeau
- Head of Medical Oncology/Hematology
- Toronto Sunnybrook Regional Cancer Centre
- Toronto, ON

- Timothy J. Whelan MD
- Active Staff
- CCO Hamilton Regional Cancer Centre
- Hamilton, ON

- Rodger J. Winn, MD
- National Quality Forum
- Houston, TX

The UO-EPC gratefully acknowledges the following individuals who reviewed the initial draft of this evidence report, and provided constructive feedback. Acknowledgment does not reflect endorsement of this report.

- David Atkins, MD, MPH
- Chief Medical Officer
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- Rockville, MD

- Thomas A. Buchholtz, MD
- Associate Professor
- M.D. Anderson Cancer Center
- Department of Radiation Oncology
- University of Texas
- Houston, TX

- Molla Sloane Donaldson, Dr.P.H., M.S.
- Senior Scientist for Quality of Care Research and Policy
- Outcomes Research Branch,
- National Cancer Institute
- Rockville, MD

- Suzanne W. Fletcher, MD, MSc
- Professor of Ambulatory Care and Prevention
- Harvard Medical School
- Chapel Hill, NC

- Beth Kosiak, Ph.D.
- AHRQ/CQuIPS
- Rockville, MD

- David I. Lewin, MPhil
- Technical Publications Writer-Editor
- Office of Communications and Knowledge Transfer
- Agency for Healthcare Research and Quality
- Rockville, MD

- Maurice McGregor, MD
- Department of Medicine
- Royal Victoria Hospital
- Montreal, QC

- Dr. Mark Richard Somerfield
- American Society of Clinical Oncology
- Alexandria, VA

- Rodger J. Winn, MD
- National Quality Forum
- Houston, TX

- Antonio C. Wolff, MD
- Assistant Professor, Oncology Center
- School of Medicine Dept. Oncology - Breast Cancer
- Johns Hopkins University
- Baltimore, MD