# Appendix H. Listing of Reference Standards

## Listing of Reference Standards Used to Measure Quality of Breast Cancer Care in Included Studies

Author, Year | Reference standard(s) | Source(s)
Appleton, 1998 ^109^ | • NHSBSP guidelines, 1991-1992 | • Royal College of Pathologists Working Group. Pathology reporting in breast cancer screening. Sheffield: NHSBSP Publications, 1989
Bernhard, 1997 ^110^ | • IBCSG form for assessing impact of adjuvant therapy on QOL | • Hürny C, Bernhard J, Gerber RD et al. Quality of life measures for patients receiving adjuvant therapy for breast cancer: An International Trial. The International Breast Cancer Study Group. Eur J Cancer 1992;28:118–24
| • LASA scales (physical well-being; mood; appetite) | • Coates A, Fisher Dillenbeck CF, McNeil DR et al. On the receiving end II. Linear analogue self-assessment (LASA) in evaluation of aspects of the quality of life of cancer patients receiving chemotherapy. Eur J Cancer Clin Oncol 1983; 19: 1633–7
Bickell, 2000 ^111^ | • Mount Sinai Health Final Guidelines for Stage I & II BC treatment, 1994-1995 | • Bickell NA, Aufses AH Jr, Chassin MR. Engaging clinicians in a QI strategy for early-stage breast cancer treatment. Qual Manag Health Care 1998; 6:63–68
Bickell, 2003 ^112^ | • Mount Sinai Health Final Guidelines for Stage I–II BC treatment, 1994-1995 | • Bickell NA, Aufses AH Jr, Chassin MR. Engaging clinicians in a QI strategy for early-stage breast cancer treatment. Qual Manag Health Care 1998; 6:63–68
Bower, 2000 ^113^ | • RAND 36-item Health Survey 1.0 | • Hays RD, Sherbourne CD, Mazel RM. The RAND 36-item Health Survey 1.0. Health Econ 1993; 2:217–227
| | • Ware JE Jr, Sherbourne CD: A 36-item Short Form Health Survey (SF-36): I. Conceptual framework and item selection. Med Care 1992; 30:473–83
Brenin, 1999 ^114^ | • NIH Consensus Development Conference, 1990 | • Treatment of early stage breast cancer. NIH Consensus Statement. 1990; 8:1–19
Cheung, 1999 ^116^ | • BASO guidelines, 1995 | • Breast Surgeons Group of the British Association of Surgical Oncology. Guidelines for Surgeons in the management of symptomatic breast disease in the United Kingdom. Eur J Sur Oncol 1995; 21 (Suppl. A)
Chie,1999 ^117^ | • SF-36 Chinese version | • New England Medical Center Hospital: IQOLA SF-36 Taiwan Standard version 1.0. Boston: The Health Institute, New England Medical Center, 1996
| • EORTC-QLQ-C30 | • EORTC Quality of Life Study Group: Questionnaire of the Department of Obstetrics and Gynecology, Hong Kong University (EORTC QLQ-C30 version 2.0). Brussels: Quality of Life Unit, EORTC Data Center, 1997
Christensen, 2002 ^118^ | • European Guidelines for Quality Assurance in Mammography screening, 1996 -Guidelines for cytology procedures and reporting in BC screening, 1993 | • European Guidelines for Quality Assurance in Mammography Screening. 2nd ed. Brussels: European Commission, 1996
| | • Guidelines for Cytology Procedures and reporting in Breast Cancer Screening. Sheffield: Cytology Sub-group of the National Coordinating Committee for Breast Screening Pathology, 1993
Cochrane, 1997 ^119^ | • NHSBSP breast referral guidelines, 1995 | • Austoker J, Mansel R, Baum M et al. Guidelines for the Referral of Patients with Breast Problems. NHS Breast Screening Programme on behalf of the Department of Health Advisory Committee on Breast Screening, 1995
Cornfeld, 2001 ^120^ | • NCCN Guidelines, 1999 | • Carlson RW. (Panel Chair) for NCCN Breast Cancer Practice Guidelines Panel Members. Update: NCCN Practice Guidelines for the Treatment of Breast Cancer. Oncology. 1999; 13:187–218
Craft, 2000 ^121^ | • NHMRC CPG for the management of early BC, 1995 | • National Health and Medical Research Council. Clinical Practice Guidelines. The management of early breast cancer. Canberra: NHMRC, 1995
DeMichele, 2003 ^122^ | • St. Gallen Consensus Conference, 1992-1995 (update) | • Glick J, Gerber R, Goldhirsch A et al. Meeting Highlights: adjuvant therapy for primary breast cancer. J Natl Cancer Inst 1992;84:1479–1485
| | • Goldhirsch A, Glick J, Gerber R et al. Meeting Highlights: international consensus panel on the treatment of primary breast cancer. J Natl Cancer Inst 1998;90:1601–8
Du, 2001 ^124^ | • NIH Consensus Conference Development, 1990 | • NIH Consensus Conference. Adjuvant chemotherapy for breast cancer. JAMA 1985;254:3461–3
| | • NIH Consensus Conference. Treatment of early-stage breast cancer. JAMA 1991;265:391–5
Du, 2003 ^125^ | • NIH Consensus Development Conference, 1990 | • NIH Consensus Conference. Adjuvant chemotherapy for breast cancer. JAMA 1985;254:3461–3
| | • NIH Consensus Conference. Treatment of early-stage breast cancer. JAMA 1991;265:391–5
Edge, 2002 ^126^ | • NIH Consensus Development Conference 1990 | • Early stage breast cancer: consensus statement. NIH Consensus Development Conference, June 18–21, 1990. cancer Treat Res 1992;60:383–393
| • Steering committee on CPGs for the care & treatment of BC, CARO | • The Steering Committee on Clinical Practice Guidelines for the care and treatment of breast cancer. Axillary dissection. Canadian Association of Radiation Oncologists. CMAJ 1998;158(Suppl 3):S22–S26
Engel, 2002 ^127^ | • NIH Consensus Development Conference, 1990 | • Lazovich D, Solomon CC, Thomas DB et al. Breast Conservation therapy in the United States following the 1990 NIH Consensus Development Conference on the treatment of patients with early stage invasive breast carcinoma. Cancer 1999;86:628–37
| • St. Gallen's Consensus for adjuvant systemic therapy, 1995-1998 (update) | • Goldhirsch A, Glick J, Gerber R et al. Meeting Highlights: international consensus panel on the treatment of primary breast cancer. J Natl Cancer Inst 1998;90:1601–8
Foroudi, 2002 ^128^ | • NCI's physician Data Query treatment Options | • National Cancer Institute. CancerNet: A service of the National Cancer Institute: PDQ Cancer Information Summaries: Treatment. Monograph on line. Accessed September 2001. url: http://cancernet.nci.nih.gov/pdq/pdq_treatment.shtml.
| • Cancer Care Ontario Clinical Practice Guidelines | • Cancer Care Ontario Practice Guidelines Initiative. Breast
| • Clinical Practice Guidelines for the Care and Treatment of Breast Cancer: A Canadian Consensus Document | • Cancer clinical practice guidelines. Monograph on line. Accessed September 2001. url:http://hiru.mcmaster.ca/ccopgi/brecpg.html.
| • NIH Consensus Conference on the Treatment of Early Stage Breast Cancer | • Anonymous. Clinical practice guidelines for the care and treatment of breast cancer: A Canadian consensus document.Can Med Assoc J 1998;158(Suppl. 3):S1–S83.
| • National Comprehensive Cancer Network Clinical Practice Guidelines | • Anonymous. Early stage breast cancer—NIH consensus conference. JAMA 1991;265:391–395.
| • British Columbia Cancer Agency's Cancer Management Manual | • Carlson RW, Goldstein LJ, Gradishar WJ, et al. Update of the NCCN guidelines for treatment of breast cancer. Oncology 1997;11:199–220.
| • Diseases of the Breast | • British Columbia Cancer Agency. Cancer management manual. Monograph on line. Accessed December 1999. url: http://www.bccancer.bc.ca/pg_g_04.asp?PageID _ 1109&Parent-ID _ 4/.
| • American Colleges of Radiology, Surgery, and Pathology's Standards for Breast Conservation Treatment | • Harris DM, Lippman ME, Morrow M, et al. Diseases of the breast. 2nd ed. Philadelphia: Lippincott Williams & Wilkins; 2000.
| • American College of Radiology's Appropriateness Criteria | • Winchester DP, Cox JD. Standards for breast conservation treatment. Cancer 1992;42:134–163.
| • Scottish Intercollegiate guidelines Network's National Clinical Guidelines | • American College of Radiology Task Force on Appropriateness Criteria. Appropriateness criteria for imaging and treatment decisions in radiation oncology. Reston, VA: American College of Radiology; 1999.
| • UK Royal College of Radiology's Clinical Oncology Information Network Guidelines | • Scottish Intercollegiate Guidelines Network. Management of breast cancer. Monograph on line. Accessed September 2001. url:http://www.show.scot.nhs.uk/sign/pdf/sign29.pdf
| • British Association of Surgical Oncology's Symptomatic Breast Disease Guidelines | • Royal College of Radiologists Clinical Oncology Information Network (COIN). Guidelines on the non-surgical management of breast cancer. Monograph on line. Accessed September 2001. url:http://www.rcr.ac.uk/breast.pdf.
| | • BASO Breast Surgeons Group. The guidelines for surgeons in the management of symptomatic breast disease. Eur J Surg Oncol 1996;22:465–476.
Frazer, 1998 ^129^ | • 39-item Guttman scaled HSQ Questionnaire form | • Radosevich DM, Wetzler H, Wilson SM. Health Status Questionnaire (HSQ) 2.0: Scoring Comparisons and Reference Data. Bloomington MN: Health Outcomes Institute, 1995, 1–70
Guadagnoli, 1997 ^130^ | • EBCTCG meta-analysis, 1992 | • Early Breast Cancer Trialists' Collaborative Group: Systematic treatment of early breast cancer by hormonal, cytotoxic, or immune therapy: 133 randomized trials involving 31,000 recurrences and 34,000 deaths among 75,000 women. Part 2. Lancet 1992;339:71–85
Guadagnoli, 1998a ^131^ | • NIH Consensus Development Conference, 1990 | • NIH Consensus Conference. Treatment of early-stage breast cancer. JAMA 1991;265:391–5
Guadagnoli, 1998b ^132^ | • NIH Consensus Development Conference, 1990 | • NIH Consensus Conference. Treatment of early-stage breast cancer. JAMA 1991;265:391–5
Haas, 2000 ^133^ | • Harvard Risk Management Foundation guidelines, 1995 | • Smith B. Algorithms for management of common breast complaints. Forum: Harvard Risk Management Foundation. July 1995: 1–5
Harlan, 2002 ^134^ | • NIH Consensus Development Conference, 1990 | • NIH Consensus Conference. Treatment of early-stage breast cancer. JAMA 1991;265:391–5
Hassey Dow, 2000 ^123^ | • Ferrans Quality-of-Life Index- cancer version (QLI) 1990 | • Ferrans CE (1990). Development of a quality-of-life index for patients with Cancer. Oncol Nurs Forum, 17(Suppl.3), 15–19
Hebert-Croteau, 1999 ^135^ | • NIH Consensus Development Conference, 1990 | • NIH Consensus Conference. Treatment of early-stage breast cancer. JAMA 1991;265:391–5
Hislop, 2003 ^136^ | • BCCA cancer treatment policy manual, 1995 | • Breast Tumor Group. In: Cancer Treatment Policies, 3rd ed. Vancouver, BC: Cancer Control Agency of British Columbia, 1988
Imperato, 2002 ^137^ | • CAP & ADASP guidelines 1997/2000 (update) | • Henson DE, Oberman HA, Hutter RVP et al. Practice protocol for the examination of specimens removed from patients with cancer of the breast. Publication of the Cancer Committee, College of American Pathologists. Arch Pathol Lab Med 1997;121:27
| | • Fechner RE, Kempson RL, Livolsi VA et al. Recommendations for the reporting of breast carcinoma. Association of Directors of Anatomic and Surgical Pathology. Am J Clin Pathol 1995;104:614
| | • Fitzgibbons PL, Connolly JL, Page DL. Updated protocol for the examination of specimens from patients with carcinoma of the breast. A basis for checklists. Arch Pathol Lab Med 2000;124:966
Jackson, 1999 ^138^ | • BCCA guidelines, 1986, update in 1989 & 1993 | • Breast Tumor Group. In: Cancer Treatment Policies, 5th ed. Vancouver, BC: Cancer Control Agency of British Columbia, 1995
| | • BC Cancer Agency. Division of Radiation Oncology. Radiotherapy treatment techniques: breast and prostate sections. Vancouver, BC: Cancer Agency. Division of Radiation Oncology; 1981-1996
Jansen, 2000 ^139^ | • Rotterdam Symptom Checklist (RSCL) | • De Haes JC, Olschewski M. Quality of life assessment in cross-cultural context: Use of Rotterdam Symptom Checklist in a multinational randomized trial comparing CMF and Zoladex (Goserlin) treatment in early breast cancer. Ann Oncol 1998;9:745–750
| • SF-36 | • Ware JE, Sherbourne CD. The MOS 36-item Short-Form health status survey (SF-36):1. Conceptual framework and item selection. Med Care 1992;30:473–483
Keating, 2001 ^140^ | • NIH Consensus Development Conference, 1990 | • National Institutes of Health Consensus Development Conference Statement. Treatment of early stage breast cancer. Paper presented at: NIH Consensus Development Conference; June 18–21, 1990; Bethesda, MD
Khawaja, 2001 ^141^ | • BASO breast group recommendations 1995/1998 (update) | • BASO Breast Surgeons Group. The guidelines for surgeons in the management of symptomatic breast disease. Eur J Surg Oncol 1996;22:465–476
| | • BASO Breast Surgeons Group. The guidelines for surgeons in the management of symptomatic breast disease. Eur J Surg Oncol 1998;24:464–476
Legorreta, 2000 ^144^ | • NIH Consensus Development Conference, 1990 | • NIH Consensus Conference. Treatment of early-stage breast cancer. JAMA 1991;265:391–5
Lazovich, 1997 ^142^ | • NIH Consensus Development Conference, 1990 | • NIH Consensus Conference. Treatment of early-stage breast cancer. JAMA 1991;265:391–5
Lazovich, 1999 ^143^ | • NIH Consensus Development Conference, 1990 | • NIH Consensus Conference. Treatment of early-stage breast cancer. JAMA 1991;265:391–5
Mandelblatt, 2001 ^145^ | • NIH Consensus Development Conference, 1990 | • NIH Consensus Conference. Treatment of early-stage breast cancer. JAMA 1991;265:391–5
Mandelblatt, 2002 ^146^ | • NIH Consensus Development Conference, 1990 | • NIH Consensus Conference. Treatment of early-stage breast cancer. JAMA 1991;265:391–5
McCarthy, 1997 ^147^ | • Quality assurance guidelines (NHSBSP), 1994 | • Quality Assurance Guidelines for Surgeons in Breast Cancer Screening. NHSBSP Publication No 20, 1994:1–45
McGlynn, 2003 ^173^ | • From observational studies and expert opinion, to randomized controlled trials | • Not reported
Molenaar, 2001 ^148^ | • IKA/IKST: Working group on Mamma Carcinoma; treatment guidelines; the Netherlands; Comprehensive Cancer Center, 1995 | • IKA/IKST: Working group on Mamma Carcinoma: IKA/IKST treatment guidelines Mamma Carcinoma. Amsterdam, the Netherlands; Comprehensive Cancer Center, 1995
| • Generic QOL MOS20 | • Kempen GI. Assessment of health status among the elderly; an application of a Dutch version of MOS-survey. Tijdschr Gerontol Geriatr 1992;23:132–140
| • EORTC QLQ-BR23 | • Saprangers MAG, Groenvold M, Arraras JI et al. The European Organization Research and Treatment of Cancer Breast Cancer-specific Quality-of-Life Questionnaire Module: First results from a three-country field study. J Clin Oncol 1996;14:2756–2768
Mor, 1994 ^149^ | • MHI-5 | • Stewart AL, Hays RD, Ware JE Jr: The MOS short form general health survey: reliability and validity in patient populations. Med Care 1981;26:724
Mor, 2000 ^150^ | • NCI Consensus Conference for surgeons, 1993 | • Published in this article (Ref 150)
Morrow, 2001; ^151^ | • ACOS, ACR, CAP, SSO guidelines, 1992 | • Winchester DP, Cox JD: Standards for breast-conservation treatment. CA Cancer J Clin 1992;42:134–176
White, 2003 ^166^
Nattinger, 2000 ^152^ | • NIH Consensus Development Conference, 1990 | • National Institutes of Health Consensus Development Conference Statement. Treatment of early stage breast cancer. Paper presented at: NIH Consensus Development Conference; June 18–21, 1990; Bethesda, MD
Northouse, 1999 ^115^ | • BC specific version of 37-item scale FACT-B, 1993 | • Cella DF, Tulsky DS, Gray G et al. The Functional Assessment of Cancer Therapy Scale: Development and validation of the general measure. J Clin Oncol 1993; 11:570–579
Osoba, 1999 ^153^ | • Self-administered EORTC core QOLQ- C30 (30 items) | • Fayers P, Aaronson N, Bjordal K et al. EORTC QLQ-C30 Scoring Manual. Brussels, Belgium, Quality of Life Unit, EORTC Data Centre, 1995
Ottevanger, 2002 ^154^ | • Regional Guidelines (CCCE) (year: NR) | • Not published
Palazzi, 2002 ^155^ | • SGCC, 1995 | • Goldhirsch A, Wood WC, Senn HJ et al. Meeting Highlights: international consensus panel on the treatment of primary breast cancer. J Natl Cancer Inst 1995;87:1441–5
Perez, 2001 ^156^ | • HRQOL scale: Spitzer QLI & uniscale questionnaire (scale 0–100) | • Spitzer WO, Dobson AJ, Hall J, et al. Measuring the quality of life of cancer patients. J Chron Dis 1981; 34: 585–597
| • TTO
Ray-Coquard, 1997 ^157,^ ^158^ | • Regional CPG, 1993; implemented, 1994 | • Not reported
Ray-Coquard, 2002 ^159^ | • Regional (ONCORA) CPG, 1995 | • Not reported
Sauven, 2003 ^160^ | • NHSBSP surgical standards,1992 | • NHSBSP. Quality Assurance Guidelines for Surgeons in Breast Cancer Screening. Publication no. 20; NHSBSP: Sheffield, 1992
Sawka, 1997 ^161^ | • Guidelines of British Columbia, 1991 | • Olivotto I, Bajdik C, Plenderleith I et al. Adjuvant systemic therapy and survival from breast cancer. N Engl J Med 1994; 330:805–10
| | • Browman GP, Levine MN, Mohide E et al. The practice guidelines development and implementation. J Clin Oncol 1995;13:502–12
Shank, 2000 ^162^ | • ACR, ACS, CAP & SSO standards for breast conservation treatment, 1992 | • Winchester DP, Cox JD: Standards for breast-conservation treatment. CA Cancer J Clin 1992;42:134–176
Silliman, 1999 ^163^ | • NIH Consensus Development Conference, 1990 | • NIH Consensus Conference. Treatment of early-stage breast cancer. JAMA 1991;265:391–5
Solin, 1999 ^164^ | • NIH Consensus Development Conference, 1990 | • NIH Consensus Conference. Treatment of early-stage breast cancer. JAMA 1991;265:391–5
Tyldesley, 2003 ^165^ | • NCI's physician Data Query treatment Options | • National Cancer Institute. CancerNet: A service of the National Cancer Institute: PDQ Cancer Information Summaries: Treatment. Monograph on line. Accessed September 2001. url: http://cancernet.nci.nih.gov/pdq/pdq_treatment.shtml.
| • Cancer Care Ontario Clinical Practice Guidelines | • Cancer Care Ontario Practice Guidelines Initiative. Breast
| • Clinical Practice Guidelines for the Care and Treatment of Breast Cancer: A Canadian Consensus Document | • Cancer clinical practice guidelines. Monograph on line. Accessed September 2001. url:http://hiru.mcmaster.ca/ccopgi/brecpg.html.
| • NIH Consensus Conference on the Treatment of Early Stage Breast Cancer | • Anonymous. Clinical practice guidelines for the care and treatment of breast cancer: A Canadian consensus document. Can Med Assoc J 1998;158(Suppl. 3):S1–S83.
| • National Comprehensive Cancer Network Clinical Practice Guidelines | • Anonymous. Early stage breast cancer—NIH consensus conference. JAMA 1991;265:391–395.
| • British Columbia Cancer Agency's Cancer Management Manual | • Carlson RW, Goldstein LJ, Gradishar WJ, et al. Update of the NCCN guidelines for treatment of breast cancer. Oncology 1997;11:199–220.
| • Diseases of the Breast | • British Columbia Cancer Agency. Cancer management manual. Monograph on line. Accessed December 1999. url: http://www.bccancer.bc.ca/pg_g_04.asp?PageID _ 1109&Parent-ID _ 4/.
| • American Colleges of Radiology, Surgery, and Pathology's Standards for Breast Conservation Treatment | • Harris DM, Lippman ME, Morrow M, et al. Diseases of the breast. 2^nd^ ed. Philadelphia: Lippincott Williams & Wilkins; 2000.
| • American College of Radiology's Appropriateness Criteria | • Winchester DP, Cox JD. Standards for breast conservation treatment. Cancer 1992;42:134–163
| • Scottish Intercollegiate guidelines Network's National Clinical Guidelines | • American College of Radiology Task Force on Appropriateness Criteria. Appropriateness criteria for imaging and treatment decisions in radiation oncology. Reston, VA: American College of Radiology; 1999
| • UK Royal College of Radiology's Clinical Oncology Information Network Guidelines | • Scottish Intercollegiate Guidelines Network. Management of breast cancer. Monograph on line. Accessed September 2001.url:http://www.show.scot.nhs.uk/sign/pdf/sign29.pdf
| • British Association of Surgical Oncology's Symptomatic Breast Disease Guidelines | • Royal College of Radiologists Clinical Oncology Information Network (COIN). Guidelines on the non-surgical management of breast cancer. Monograph on line. Accessed September 2001 url:http://www.rcr.ac.uk/breast.pdf.
| | • BASO Breast Surgeons Group. The guidelines for surgeons in the management of symptomatic breast disease. Eur J Surg Oncol 1996;22:465–476
Wilkinson, 2003 ^167^ | • CAP guideline, 1998 | • Compton CC, Henson DE, Hammond EH et al. Reporting on cancer specimens: protocols and case summaries. Northfield, IL: College of American Pathologists; 1998