# Appendix G. Listing of Quality Indicators

## Listing of Quality Indicators Used to Measure Adherence to Standards of Breast Cancer Care

1. DIAGNOSIS
1.1 Preoperative diagnosis
• Appropriate use: If a palpable breast mass has been detected, at least one of the following procedures should be completed within 3 months: fine-needle aspiration, mammography, ultrasound, biopsy and/or a followup visit^IV^
• Appropriate use of preoperative mammographic evaluation^IV^
• Appropriate use of imaging &/or cytology or needle biopsy, if required, to be performed at the initial visit^IV^
• Appropriate use of preoperative diagnosis by fine-needle aspiration cytology, needle histology or biopsy^IV^
• Appropriate use: A biopsy or fine-needle aspiration should be performed within 6 weeks either when the mammography suggests malignancy or the persistent palpable mass is not cystic on ultrasound^IV^
• Appropriate use: If a breast mass has been detected on two separate occasions, then either a biopsy, fine-needle aspiration or ultrasound should be performed within 3 months of the second visit^IV^
• Quality of fine-needle aspiration samples from lesions, which subsequently prove to be breast cancer, should be adequate as deemed by the breast pathologist^IV^
1.2 Surgical procedures
• Appropriate use: A biopsy should be performed within 6 weeks if fine-needle aspiration cannot rule out malignancy^IV^
• Appropriate use of first localization biopsy operation to correctly identify impalpable lesions^IV^
• Quality of breast biopsy: primary operable breast cancer receives a frozen section^IV^
• Quality of technique to determine histological node status for all invasive tumors, either by sampling or clearance^IV^
• Quality of sampling nodes for invasive breast cancer, to include ≥ 4 nodes^IV^
• Quality of hormone receptor assay^IV^
1.3 QOL and patient satisfaction relating to diagnosis
• Change in QOL after diagnosis of breast cancer^Iac^
• Women reporting an overall satisfaction with the quality of breast care^Iac^
1.4 General category
• Appropriate use of referrals to surgeon by general practitioner according to breast referral guidelines^IV^
• >90% of women with breast cancer detected by screening should attend an assessment center within 3 weeks of mammography^IV^
• Patients attending for diagnostic purposes seen on at least 1 occasion by a breast specialist surgeon^IV^
• <10% of all new cases of women with breast cancer should attend the clinic/hospital on > 2 occasions for diagnostic purposes^IV^
• Urgent referrals of women with breast cancer to be seen within 5 working days^IV^
• Women with breast cancer to be seen by specialist in timely fashion post referral for diagnostic purposes^IV^
• Management of cases coming to surgery from the screening program carried out by surgeons who have acquired the necessary specialist knowledge^IV^
• ≥90% of women requiring an operation for diagnostic purposes should be admitted within 14 days of the surgical decision^IV^
• ≥90% of women with breast cancer or with an abnormality requiring diagnostic operation need to be told of this within 5 working days of investigations leading to this diagnosis^IV^
• Appropriate use of an evaluation in compliance with guidelines^IV^
• Appropriate use of initial examination^IV^
2. TREATMENT
2.1 Surgery
• Appropriate use: Women with stage I or stage II breast cancer should be offered a choice of modified radical mastectomy or breast-conserving surgery, unless contraindications to breast-conserving surgery are present^IV^
• Appropriate use of all surgery^IV^
• No breast-conserving surgery or mastectomy in metastatic disease^IV^
• Appropriate use of breast-conserving surgery^IV^
• Appropriate number of therapeutic operations (≤ 2) for women having breast-conserving surgery^IV^
• Appropriate use of mastectomy^IV^
• Appropriate use of axillary lymph node dissection^IV^
2.2 Radiotherapy
• Appropriate use of radiotherapy^IV^
• Appropriate use: Women treated with breast-conserving surgery should begin radiation therapy within 6 weeks of completing either of the following: the last surgical procedure on the breast (including reconstructive surgery that occurs within 6 weeks of primary resection) or chemotherapy, if patient receives adjuvant chemotherapy, unless wound complications prevent the initiation of treatment^IV^
• Appropriate use of radiotherapy after breast-conserving surgery^IV^
• Quality of radiotherapy after breast-conserving surgery (following guidelines)^IV^
• Appropriate use of radiotherapy after mastectomy^IV^
• Quality of radiotherapy via planning on a dedicated simulator^IV^
• Quality of radiotherapy: done 5 days/week^IV^
• Quality of radiotherapy: homogenous dose distribution of radiotherapy^IV^
• Quality of radiotherapy: use of wedges on tangent breast fields^IV^
• Appropriate use of radiotherapy on axilla following axillary lymph node dissection, to deal with increased risk of local recurrence (i.e. extracapsular extension; ≥ 4 positive nodes)^IV^
• Appropriate use of parasternal radiotherapy for tumors located in the medial part of breast^IV^
• Appropriate use of palliative radiotherapy for women with progression or recurrence^IV^
• Regional recurrence needing further surgery or radiotherapy^IV^
• Quality of radiotherapy: both tangent fields treated daily^IV^
• Quality of radiotherapy: receiving 4,500–5,000 cGy total breast dose given in 180–200 cGy fractions^IV^
• Quality of radiotherapy: electron beam breast radiation used^IV^
2.3 Adjuvant systemic therapy
• Appropriate use of any adjuvant systemic therapy^IV^
• Appropriate use: Women with invasive breast cancer that is node-positive, or node-negative and primary tumor ≥ 1 cm, should be treated with adjuvant systemic therapy to include combination chemotherapy (and/or tamoxifen, 20mg/d) ^IV^
• Appropriate use of any adjuvant systemic therapy in women with node (+) breast cancer^IV^
• Appropriate use of any adjuvant systemic therapy in women with node (-) breast cancer^IV^
• Appropriate use of adjuvant systemic therapy after breast-conserving surgery^IV^
• Appropriate use of tamoxifen^IV^
• Appropriate use of tamoxifen in premenopausal women with node (-), intermediate risk, breast cancer^IV^
• Appropriate use of tamoxifen in postmenopausal women with node (-), intermediate risk, breast cancer^IV^
• Appropriate use of tamoxifen in postmenopausal women with node (-), high risk, estrogen receptor (+), breast cancer^IV^
• Appropriate use of tamoxifen in postmenopausal women with node (+)^IV^
• Appropriate use of chemotherapy and hormone therapy (tamoxifen)^IV^
• Appropriate use of chemotherapy and hormone therapy (tamoxifen) in premenopausal women, node (+), hormone receptor (+), breast cancer^IV^
• Appropriate use of chemotherapy^IV^
• Appropriate use of chemotherapy in women with node (-), high risk, estrogen receptor (-), breast cancer^IV^
• Appropriate use of chemotherapy in women with node (-), estrogen receptor (+), breast cancer^IV^
• Appropriate use of chemotherapy in premenopausal women with node (-), high risk, estrogen receptor (+), breast cancer^IV^
• Appropriate use of chemotherapy in premenopausal women with node (+), estrogen receptor (-), breast cancer^IV^
• Appropriate use of chemotherapy in postmenopausal women with node (+), estrogen receptor (-), breast cancer^IV^
• Appropriate use of chemotherapy in postmenopausal women with node (+), estrogen receptor (+), breast cancer^IV^
• Appropriate use of chemotherapy in women <50 years of age with node (+), breast cancer^IV^
• Appropriate use of chemotherapy &/or ovarian ablation in premenopausal women with node (+), estrogen receptor (+), breast cancer^IV^
• Appropriate decision not to provide adjuvant systemic therapy for women node (-), low risk, breast cancer^IV^
• Appropriate decision not to provide adjuvant systemic therapy for women > 65 years of age with high risk, estrogen receptor (-), breast cancer^IV^
• Quality of chemotherapy: proper doses administered (≥ 85% dose intensity [DI] & relative dose intensity [RDI]) of CMF^IV^
• Availability of office procedure manual used for chemotherapy administration^IV^
2.4 QOL and patient satisfaction relating to treatment
• Overall changes in QOL over time, before & after radiotherapy^Iac^
• Change in QOL in women with metastatic breast cancer^Iac^
• Women with a significant improvement in QOL in clinical phases of breast cancer^Iac^
• Change in QOL by time and treatment arm in postmenopausal, node (-) breast cancer women who underwent adjuvant therapy^Ia^
• Change in QOL over time^Iac^
• Satisfaction of women with breast cancer with the treatment choice^Iac^
• Participation of women with breast cancer in decision-making as much as they wanted^IV^
• Received enough information about surgery and radiotherapy^IV^
2.5 General category
• Board certified medical doctors in medical oncology^IV^
• Documentation of Continuing Medical Education credits for the 2 years preceding audit^IV^
• Referral to oncologist for treatment^IV^
• Women with breast cancer given the opportunity to see a breast cancer specialist nurse^IV^
• Evidence of discussion about surgical options^IV^
• ≥90% of women admitted for an operation within 21 days of the surgical decision to operate for therapeutic purposes^IV^
• Appropriate use of treatment sequences according to guidelines (including surgery; radiotherapy; chemotherapy; hormone therapy; initial examination; and followup)^IV^
• Appropriate use of definitive locoregional therapy (total mastectomy + axillary lymph node dissection, or, breast-conserving surgery + axillary lymph node dissection + radiotherapy)^IV^
• Appropriate use of alternative definitive therapy (radiotherapy after breast-conserving surgery + axillary lymph node dissection or adjuvant treatment)^IV^
• Cases not receiving recommended treatment (radiotherapy after breast-conserving surgery or systemic therapy) due to system failure^IV^
• Appropriate use: Women with metastatic breast cancer should be offered hormonal therapy, chemotherapy, and/or enrollment in a clinical trial with documentation of informed consent within 6 weeks of the identification of metastases^IV^
3. Followup
• Appropriate use: Women with a history of breast cancer should have a yearly mammography^IV^
• Appropriate use of guidelines for followup surveillance of breast cancer^IV^
• Women with breast cancer developing local recurrence within 5 years after breast-conserving surgery^IV^
• Women with breast cancer developing local recurrence within 5 years after mastectomy^IV^
• Appropriate use of prophylactic radiotherapy in women with high risk of flap recurrence^IV^
4. REPORTING/DOCUMENTATION
4.1 Pathology reporting/documentation
• Reporting gross observation of lesion^IV^
• Reporting verification tumor size (microscopic)^IV^
• Reporting number of positive lymph nodes (microscopic)^IV^
• Reporting nuclear grade (microscopic)^IV^
• Reporting mitotic rate (microscopic)^IV^
• Reporting extent of tubule formation (microscopic)^IV^
• Reporting laterality of surgical specimen (gross examination)^IV^
• Reporting identification of affected quadrant (gross examination)^IV^
• Reporting the orientation of the pathology specimen (gross examination)^IV^
• Reporting size of specimen (gross examination)^IV^
• Reporting tumor size (macroscopic)^IV^
• Reporting tumor size (microscopic)^IV^
• Reporting lymph node presence/absence (gross examination)^IV^
• Reporting number of lymph nodes present (gross examination)^IV^
• Reporting nature of specimen (gross examination)^IV^
• Reporting distance of tumor from nipple (gross examination)^IV^
• Reporting description of cut surface of the tumor (gross examination)^IV^
• Reporting description of skin (gross examination)^IV^
• Reporting size of overlying skin (gross examination)^IV^
• Reporting description of nipple (gross examination)^IV^
• Reporting presence or absence of fascia or skeletal muscle (gross examination) ^IV^
• Reporting involvement of apical lymph nodes (microscopic)^IV^
• Reporting size of concurrent ductal carcinoma in situ (microscopic)^IV^
• Reporting description of background breast (microscopic)^IV^
• Reporting ductal carcinoma in situ (DCIS) present/absent (microscopic)^IV^
• Reporting measurement of macroscopic margins of carcinoma^IV^
• Reporting assessment of microscopic margins^IV^
• Reporting carcinoma confirmed microscopically^IV^
• Reporting histological type (microscopic)^IV^
• Reporting histological grade (microscopic)^IV^
• Reporting lymph-vascular invasion (microscopic)^IV^
• Reporting size of invasive carcinoma (microscopic)^IV^
• Reporting estrogen receptor status (microscopic)^IV^
• Reporting progesterone receptor status (microscopic)^IV^
• Reporting specimen inked (microscopic) ^IV^
• Reporting Bloom Scarf Richardson scale (tumor grade) (microscopic)^IV^
• Reporting TNM staging (microscopic)^IV^
• Reporting distance to the closest margin (microscopic)^IV^
• Reporting pathological extent of primary tumor (microscopic)^IV^
• Reporting having performed flow cytometry (microscopic)^IV^
• Reporting cytometry ploidy (microscopic)^IV^
• Pathology reports on chart^IV^
4.2 Imaging reporting/documentation
• Size of mammographic abnormality^IV^
4.3 Chemotherapy reporting/documentation
• Presence of chemotherapy flow sheets in active treatment charts^IV^
• Presence of body surface area calculations on chemotherapy flow sheets^IV^

Level Ia = pre-study data indicating consistently sound psychometric properties; Iac = pre- and on-study data indicating consistently sound psychometric properties; IV = no pre- or on-study psychometric data