# Appendix F. Listing of Studies Included in Evidence Tables

Appleton M A, Douglas-Jones A G, Morgan J M. Evidence of effectiveness of clinical audit in improving histopathology reporting standards of mastectomy specimens. J Clin Pathol. 1998;51(1):30-3. [pmid: 9577368]. [pmcid: 500427].
Bernhard J, Hurny C, Coates AS, et-al. Quality of life assessment in patients receiving adjuvant therapy for breast cancer: the IBCSG approach. The International Breast Cancer Study Group.[erratum appears in Ann Oncol. 1998;9(2):231]. Ann Oncol 1997;8(9):825-35.
Bickell N A, Aufses A H Jr, Chassin M R. The quality of early-stage breast cancer care. Ann Surg. 2000;232(2):220-4. [pmid: 10903601]. [pmcid: 1421134].
Bickell N A, McEvoy M D. Physicians' reasons for failing to deliver effective breast cancer care: a framework for underuse.[comment]. Med Care. 2003;41(3):442-6. [pmid: 12618647].
Bower J E, Ganz P A, Desmond K A, et al. Fatigue in breast cancer survivors: Occurrence, correlates, and impact on quality of life. J Clin Oncol. 2000;18:743-53. [pmid: 10673515].
Brenin D R, Morrow M, Moughan J, et al. Management of axillary lymph nodes in breast cancer: a national patterns of care study of 17,151 patients. Ann Surg. 1999;230(5):686-91. [pmid: 10561093]. [pmcid: 1420923].
Northouse L L, Caffey M, Deichelbohrer L, et al. The quality of life of African American women with breast cancer. Res Nurs Health. 1999;22:449-60. [pmid: 10630287].
Cheung K L. Management of primary breast cancer in Hong Kong—can the guidelines be met?. Eur J Surg Oncol. 1999;25(3):255-60. [pmid: 10336803].
Chie W C, Huang C S, Chen J H, et al. Measurement of the quality of life during different clinical phases of breast cancer. J Formos Med Assoc. 1999;98(4):254-60. [pmid: 10389369].
Christensen L B, Rank F E, Blichert-Toft M, et al. [Mammographic screening in the municipality of Copenhagen 1991-1997. Evaluation of the preoperative assessment]. [Danish]. Ugeskr Laeger. 2002;164(2):191-5. [pmid: 11831088].
Cochrane R A, Singhal H, Monypenny I J, et al. Evaluation of general practitioner referrals to a specialist breast clinic according to the UK national guidelines. Eur J Surg Oncol. 1997;23(3):198-201. [pmid: 9236889].
Cornfeld M J, Jadwin A, O'Grady P, et al. Feasibility of assessing quality in medical oncology practices. Cancer Pract. 2001;9(5):231-5. [pmid: 11879319].
Craft P S, Zhang Y, Brogan J, et al. Implementing clinical practice guidelines: a community-based audit of breast cancer treatment. Australian Capital Territory and South Eastern New South Wales Breast Cancer Treatment Group.[comment]. Med J Aust. 2000;172(5):213-6. [pmid: 10776392].
DeMichele A, Putt M, Zhang Y, et al. Older age predicts a decline in adjuvant chemotherapy recommendations for patients with breast carcinoma: evidence from a tertiary care cohort of chemotherapy-eligible patients. Cancer. 2003;97(9):2150-9. [pmid: 12712466].
Dow K H, Lafferty P. Quality of life, survivorship, and psychosocial adjustment of young women with breast cancer after breast-conserving surgery and radiation therapy. Oncol Nurs Forum. 2000;27:1555-64. [pmid: 11103374].
Du X, Goodwin J S. Increase of chemotherapy use in older women with breast carcinoma from 1991 to 1996. Cancer. 2001;92(4):730-7. [pmid: 11550141].
Du X L, Key C R, Osborne C, et al. Discrepancy between consensus recommendations and actual community use of adjuvant chemotherapy in women with breast cancer.[summary for patients in Ann Intern Med. 2003 Jan 21;138(2):I16; PMID: 12529113]. Ann Intern Med. 2003;138(2):90-7. [pmid: 12529090].
Edge S B, Gold K, Berg C D, et al. Patient and provider characteristics that affect the use of axillary dissection in older women with stage I–II breast carcinoma. Cancer. 2002;94(10):2534-41. [pmid: 12173318].
Engel J, Nagel G, Breuer E, et al. Primary breast cancer therapy in six regions of Germany. Eur J Cancer. 2002;38(4):578-85. [pmid: 11872353].
Foroudi F, Tyldesley S, Walker H, et al. An evidence-based estimate of appropriate radiotherapy utilization rate for breast cancer. Int J Radiat Oncol Biol Phys. 2002;53(5):1240-53. [pmid: 12128126].
Frazer G H, Brown C H III, Graves T K. A longitudinal outcome assessment of quality of life indicators among selected cancer patients. J Rehab Outcomes Measures. 1998;2(2):40-7.
Guadagnoli E, Shapiro C, Gurwitz J H, et al. Age-related patterns of care: evidence against ageism in the treatment of early-stage breast cancer. J Clin Oncol. 1997;15(6):2338-44. [pmid: 9196148].
Guadagnoli E, Shapiro C L, Weeks J C, et al. The quality of care for treatment of early stage breast carcinoma: is it consistent with national guidelines?. Cancer. 1998;83(2):302-9. [pmid: 9669813].
Guadagnoli E, Weeks J C, Shapiro C L, et al. Use of breast-conserving surgery for treatment of stage I and stage II breast cancer. J Clin Oncol. 1998;16(1):101-6. [pmid: 9440729].
Haas J S, Cook E F, Puopolo A L, et al. Differences in the quality of care for women with an abnormal mammogram or breast complaint.[comment]. J Gen Intern Med. 2000;15(5):321-8. [pmid: 10840267]. [pmcid: 1495454].
Harlan L C, Abrams J, Warren J L, et al. Adjuvant therapy for breast cancer: practice patterns of community physicians. J Clin Oncol. 2002;20(7):1809-17. [pmid: 11919238].
Hebert-Croteau N, Brisson J, Latreille J, et al. Compliance with consensus recommendations for the treatment of early stage breast carcinoma in elderly women. Cancer. 1999;85(5):1104-13. [pmid: 10091795].
Hislop T G, Coldman A J, Olivotto I A, et al. Local and regional therapy for women with breast cancer in British Columbia. Breast J. 2003;9(3):192-9. [pmid: 12752627].
Imperato P J, Waisman J, Wallen M, et al. Breast cancer pathology practices among Medicare patients undergoing unilateral extended simple mastectomy. J Womens Health Gend Based Med. 2002;11(6):537-47. [pmid: 12225627].
Jackson S M, Baerg B. Compliance with radiation treatment guidelines in a provincial setting. Cancer Prev Control. 1999;3(3):196-201. [pmid: 10474767].
Jansen S J, Stiggelbout A M, Nooij M A, et al. Response shift in quality of life measurement in early-stage breast cancer patients undergoing radiotherapy. Qual Life Res. 2000;9(6):603-15. [pmid: 11236851].
Keating N L, Weeks J C, Landrum M B, et al. Discussion of treatment options for early-stage breast cancer: effect of provider specialty on type of surgery and satisfaction. Med Care. 2001;39(7):681-91. [pmid: 11458133].
Khawaja A R, Allan S M. Audit of referral practice to a fast-access breast clinic before the guaranteed 2-week wait. Ann R Coll Surg Engl. 2001;83(1):58-60. [pmid: 11212454].
Lazovich D, White E, Thomas D B, et al. Change in the use of breast-conserving surgery in western Washington after the 1990 NIH Consensus Development Conference. Arch Surg. 1997;132(4):418-23. [pmid: 9108764].
Lazovich D, Solomon C C, Thomas D B, et al. Breast conservation therapy in the United States following the 1990 National Institutes of Health Consensus Development Conference on the treatment of patients with early stage invasive breast carcinoma. Cancer. 1999;86(4):628-37. [pmid: 10440690].
Legorreta A P, Liu X, Parker R G. Examining the use of breast-conserving treatment for women with breast cancer in a managed care environment. Am J Clin Oncol. 2000;23(5):438-41. [pmid: 11039500].
Mandelblatt J S, Berg C D, Meropol N J, et al. Measuring and predicting surgeons' practice styles for breast cancer treatment in older women. Med Care. 2001;39(3):228-42. [pmid: 11242318].
Mandelblatt J S, Kerner J F, Hadley J, et al. Variations in breast carcinoma treatment in older medicare beneficiaries: is it black or white. Cancer. 2002;95(7):1401-14. [pmid: 12237908].
McCarthy D O, Blamey R W, Robertson J F, et al. A one-year audit of 255 operable breast cancers. Eur J Surg Oncol. 1997;23(5):399-402. [pmid: 9393566].
McGlynn E A, Asch S M, Adams J, et al. The quality of health care delivered to adults in the United States. N Engl J Med. 2003;348(26):2635-45. [pmid: 12826639].
Molenaar S, Sprangers M A, Rutgers E J, et al. Decision support for patients with early-stage breast cancer: effects of an interactive breast cancer CDROM on treatment decision, satisfaction, and quality of life. J Clin Oncol. 2001;19(6):1676-87. [pmid: 11250997].
Mor V, Malin M, Allen S. Age differences in the psychosocial problems encountered by breast cancer patients. J Natl Cancer Inst Monogr 1994;(16):191–7.
Mor V, Laliberte L L, Petrisek A C, et al. Impact of breast cancer treatment guidelines on surgeon practice patterns: results of a hospital-based intervention. Surgery. 2000;128(5):847-61. [pmid: 11056451].
Morrow M, White J, Moughan J, et al. Factors predicting the use of breast-conserving therapy in stage I and II breast carcinoma.[comment]. J Clin Oncol. 2001;19(8):2254-62. [pmid: 11304779].
Nattinger A B, Hoffmann R G, Kneusel R T, et al. Relation between appropriateness of primary therapy for early-stage breast carcinoma and increased use of breast-conserving surgery [comment]. Lancet. 2000;356(9236):1148-53. [pmid: 11030294].
Osoba D, Burchmore M. Health-related quality of life in women with metastatic breast cancer treated with trastuzumab (Herceptin). Semin Oncol. 1999;26(4 Suppl 12):84-8. [pmid: 10482198].
Ottevanger P B, De Mulder P H, Grol R P, et al. Effects of quality of treatment on prognosis in primary breast cancer patients treated in daily practice. Anticancer Res. 2002;22(1A):459-65. [pmid: 12017333].
Palazzi M, De Tomasi D, D'Affronto C, et al. Are international guidelines for the prescription of adjuvant treatment for early breast cancer followed in clinical practice? Results of a population-based study on 1547 patients. Tumori. 2002;88(6):503-6. [pmid: 12597147].
Perez D J, Williams S M, Christensen E A, McGee R O, Campbell A V. A longitudinal study of health related quality of life and utility measures in patients with advanced breast cancer. Qual Life Res. 2001;10:587-93. [pmid: 11822792].
Ray-Coquard I, Philip T, Lehmann M, et al. Impact of a clinical guidelines program on medical practice in a French cancer center (Meeting abstract). J Clin Oncol. 1997;16.
Ray-Coquard I, Philip T, Lehmann M, et al. Impact of a clinical guidelines program for breast and colon cancer in a French cancer center. JAMA. 1997;278(19):1591-5. [pmid: 9370505].
Ray-Coquard I, Philip T, de Laroche G, et al. A controlled “before-after” study: impact of a clinical guidelines programme and regional cancer network organization on medical practice. Br J Cancer. 2002;86(3):313-21. [pmid: 11875690].
Sauven P, Bishop H, Patnick J, et al. The National Health Service Breast Screening Programme and British Association of Surgical Oncology audit of quality assurance in breast screening 1996-2001. Br J Surg. 2003;90(1):82-7. [pmid: 12520580].
Sawka C, Olivotto I, Coldman A, et al. The association between population-based treatment guidelines and adjuvant therapy for node-negative breast cancer. British Columbia/Ontario Working Group. Br J Cancer. 1997;75(10):1534-42. [pmid: 9166950].
Shank B, Moughan J, Owen J, et al. The 1993-94 patterns of care process survey for breast irradiation after breast-conserving surgery-comparison with the 1992 standard for breast conservation treatment. The Patterns of Care Study, American College of Radiology. Int J Radiat Oncol Biol Phys. 2000;48(5):1291-9. [pmid: 11121625].
Silliman R A, Demissie S, Troyan S L. The care of older women with early-stage breast cancer: what is the role of surgeon gender?. Med Care. 1999;37(10):1057-67. [pmid: 10524372].
Solin L J, Schultz D J, Hanchak N A, et al. Patterns of treatment for older women with newly diagnosed breast carcinoma. Am J Clin Oncol. 1999;22(2):107-13. [pmid: 10199441].
Tyldesley S, Foroudi. The appropriate rate of breast conserving surgery: an evidence-based estimate. Clin Oncol (R Coll Radiol). 2003;15(3):144-55. [pmid: 12801054].
White J, Morrow M, Moughan J, et al. Compliance with breast-conservation standards for patients with early-stage breast carcinoma. Cancer. 2003;97(4):893-904. [pmid: 12569588].
Wilkinson N W, Shahryarinejad A, Winston J S, et al. Concordance with breast cancer pathology reporting practice guidelines.[comment]. J Am Coll Surg. 2003;196(1):38-43. [pmid: 12517547].