# Appendix B. Letter to Society Representative

## Letter to American Cancer Society of Clinical Oncology

Mark Somerfield PhD

Director, Cancer Policy and Clinical Affairs

American Society of Clinical Oncology

1900 Duke Street, Suite 200

Alexandria, VA 22314.

October 1, 2003.

Dear Mark:

Thanks for speaking with me yesterday. I have copied our AHRQ representative on this email since she, I am certain, will be most pleased that we have been able to speak.

To restate our request, we at the University of Ottawa Evidence-based Practice Center, under contract from AHRQ, are doing a systematic review of quality measures regarding breast cancer diagnosis and treatment (see attached RFTO), and we would like to integrate into our evidence report specific information and data we understand ASCO has been, and is still, collecting:

a. the quality measures exclusively pertaining to our topic (i.e., less than the total of 108), including information/data about:
b. their exact definition;
c. their developmental history (rationale; protocol for development; pilot test data, including psychometric history and specific links to improved outcomes; databases used for case identification) as well as their source(i.e., systematic reviews; guidelines; peer review process; some combination thereof); and,
d. their subsequent performance in the field following their establishment as ‘viable’ quality measures, including any protocols for their implementation, databases used for case identification, etc. I would welcome any additional opportunity to clarify our work, or to do whatever facilitates this process.

Perhaps you or your representative would like to become involved in our process, for example, as part of an Expert Panel.

I look forward to hearing back from you.

Sincerely,

Howard Schachter PhD

University of Ottawa Evidence-based Practice Center

CC: Stacie Jones, AHRQ