# Appendix A. Search Strategies

## Search Strategy 1

1. breast cancer.tw.
2. exp breast neoplasms/
3. breast$.tw.
4. exp breast/
5. exp neoplasms/
6. (3 or 4) and 5
7. ((breast$ or mammar$) adj2 (neoplasm$ or cancer$ or tumour$ or tumor$ or carcinoma$ or adenocarcinoma$ or dcis or ductal or infiltrating or intraductal or lobular or medullary)).tw.
8. or/1–2,6–7
9. quality of health care/
10. Guideline Adherence/
11. Medical Audit/
12. Nursing Audit/
13. “Outcome and Process Assessment (Health Care)”/
14. “Commission on Professional and Hospital Activities”/
15. “Outcome Assessment (Health Care)”/
16. “Process Assessment (Health Care)”/
17. “Peer Review, Health Care”/
18. “Professional Review Organizations”/
19. Program Evaluation/
20. Benchmarking/
21. Quality Assurance, Health Care/
22. Guidelines/
23. Practice Guidelines/
24. “Total Quality Management”/
25. “Quality Indicators, Health Care”/
26. Utilization Review/
27. practice guideline.pt.
28. Consensus Development Conference.pt.
29. ((quality or performance) adj2 (measure$ or indicator$ or assessment$)).tw.
30. “standard of care”.tw.
31. ((practice or consensus or position) adj2 (guideline$ or recommendation$ or statement$)).tw.
32. or/9–31
33. 8 and 32
34. limit 33 to yr=1993-2003
35. (diagnos$ or detect$ or treatment$ or therap$ or radiol$ or surg$ or pathol$ or instrument$ or rehab$ or chemoth$).mp.
36. (biops$ or scan or MRI or CT or genet$ or mastectomy or radiation$).mp.
37. (di or dt or ge or is or pa or ra or rt or rh or su or th).fs.
38. 34 and (35 or 36 or 37)
39. limit 38 to english language
40. 38 not 39
41. (20031$ or 20032$ or 20024$ or 20025$).ew.
42. 39 and 41
43. 40 or 42

## Search Strategy 2

1. (Breast$ or mammo$ or mamma$ or mast$).mp.
2. (cancer$ or neoplasm$).mp.
3. quality.mp.
4. 1 and 2 and 3

## Search Strategy 3

1. systematic review$.mp.
2. systematic literature review$.mp.
3. meta-analysis.pt.
4. (meta-analysis or metaanalysis or meta-analyses).ti.
5. evidence-based medicine.mp.
6. evidence-based.mp. and ((guideline or guidelines).ti. or recommendations.mp.)
7. evidenced-based.mp. and ((guideline or guidelines).tw. or recommendation$.mp.)
8. consensus development conference.pt.
9. guideline.pt.
10. health planning guidelines.mp.
11. cochrane database of systematic reviews.jn.
12. acp journal club.jn.
13. (health technology assessment reports or health technology assessment rockville md or health technology assessment winchester england).jn.
14. evidence report technology assessment summary.jn.
15. (evidence based mental health or evidence based nursing).jn.
16. clinical evidence.jn.
17. or/1–16
18. systematic.tw. or systematically.mp. or critical.tw.
19. (study and selection).ti,ab.
20. (predetermined or inclusion).mp. and criteri$.tw.
21. exclusion criteri$.mp.
22. main outcome measures.mp.
23. standard of care.mp.
24. or/18–23
25. (Survey or surveys).tw. or overview$.mp. or review.tw. or reviews.mp.
26. (search$ or handsearch).mp.
27. (analysis or critique).tw. or appraisal.mp.
28. (reduction and risk and (death or recurrence)).mp.
29. or/25–28
30. literature.tw. or articles.mp.
31. (publications or publication).tw.
32. bibliography.tw. or bibliographies.mp.
33. (published or unpublished or citation$).mp.
34. Database.mp. or internet.tw. or textbooks.tw. or references.mp.
35. trials.mp.
36. meta-analysis/
37. clinical.tw. and studies.mp.
38. treatment outcome.mp.
39. or/30–38
40. and/24,29,39
41. case report.ti.
42. case report/
43. editorial.ti.
44. (editorial or letter or newspaper article).pt.
45. or/41–44
46. (17 or 40) not 45
47. breast cancer.tw.
48. exp breast neoplasms/
49. breast$.tw.
50. exp breast/
51. exp neoplasms/
52. (49 or 50) and 51
53. ((breast$ or mammar$) adj2 (neoplasm$ or cancer$ or tumour$ or tumor$ or carcinoma$ or adenocarcinoma$ or dcis or lcis or ductal or infiltrating or intraductal or lobular or medullary)).tw.
54. or/47–48,52–53
55. (diagnos$ or detect$ or treatment$ or therap$ or radiol$ or surg$ or pathol$ or instrument$ or rehab$ or chemoth$).mp.
56. (biops$ or scan or MRI or CT or genet$ or mastectomy or radiation$).mp.
57. (di or dt or ge or is or pa or ra or rt or rh or su or th).fs.
58. or/55–57
59. 46 and 54 and 58
60. limit 59 to yr=1994-2003