# Appendices

Appendix A. Search Strategies

Appendix B. Letter to Society Representative

Appendix C. Data Assessment and Data Abstraction Forms

Appendix D. Modified QUOROM Flow Chart

Appendix E. Evidence Tables

Appendix F. Listing of Studies Included in Evidence Tables

Appendix G. Listing of Quality Indicators

Appendix H. Listing of Reference Standards

Appendix I. Additional Acknowledgments