# Abbreviations and Acronyms

95% CI- | Ninety-five percent confidence interval
AGA- | Antigliadin antibody
AR- | Attributable risk
BMD- | Bone mineral density
CD- | Celiac disease
DXA- | Dual energy X-ray absorptiometry
EGD- | Esophagogastroduodenoscopy
ELISA- | Enzyme-linked immunosorbent assay
EMA- | Endomysial antibody
ESPGAN- | European Society of Pediatric Gastroenterology and Nutrition
ETCL- | Enteropathy-associated T-cell lymphoma
GFD- | Gluten-free diet
GP- | Guinea pig
HLA- | Human leukocyte antigen
HR- | Human recombinant
HU- | Human umbilical cord
IDA- | Iron deficiency anemia
IDDM- | Type I diabetes (insulin dependent)
IEL- | Intraepithelial lymphocytes
IF- | Immunofluorescence
IgA- | Immunoglobulin A
IgG- | Immunoglobulin G
ME- | Monkey esophagus
NHL- | Non-Hodgkin's lymphoma
NPV- | Negative predictive value
OR- | Odds ratio
PPV- | Positive predictive value
Prev- | Prevalence
PVA- | Partial villous atrophy
RR- | Relative risk
SD- | Standard deviation
Sens- | Sensitivity
SIR- | Standardized incidence ratio
SMR- | Standardized mortality ratio
SPA- | Single photon absorptiometry
Spec- | Specificity
SVA- | Subtotal villous atrophy
tTG- | Tissue transglutaminase
VA- | Villous atrophy