# Conclusion

This report has provided a systematic review on five broad areas of CD, with each of these areas including important sub-components. Perhaps one of the most important findings of this report is the understanding of the importance of how one chooses to define CD in the era of serological testing, and how this apparently clear-cut task has profound implications on all the results presented in this report. Specifically, can CD be diagnosed solely on the basis of serology? Is some degree of villous atrophy necessary for the diagnosis of CD? These questions have important implications downstream of the diagnosis as well. Do CD patients without symptoms or villous atrophy have the same risk of complications as those with villous atrophy? Is serological improvement on a GFD sufficient to reduce CD complications or must there be documented histological improvement, and what degree of histological improvement is necessary?

The results of the Celiac 1 objective suggest that in the era of EMA and tTG antibody testing, AGA testing in both children and adults has a limited role. The sensitivity and specificity of EMA and tTG are quite high (over 95% for sensitivity, and close to 100% for specificity), as are their PPVs and NPVs, but as previously discussed, one has to be aware that the reported diagnostic parameters are taken from studies in which the prevalence of CD was, for the most part, much higher than that seen in usual clinical practice and certainly the PPV of these tests may not be as high as reported when these tests are applied in general population screening. The bulk of the evidence on the diagnostic characteristics of these tests was derived from studies that defined CD as having at least some degree of villous atrophy. We have identified studies that suggest that the sensitivity of these tests drops, at times significantly, when applied to populations with CD with lower-grade histological lesions. This not only has implications regarding those patients with “mild” CD who were missed during screening efforts, but also puts into question the nearly perfect NPV of these tests.

HLA DQ2/DQ8 testing appears to be a useful adjunct in the diagnosis of CD. The test has high sensitivity, in excess of 90% to 95%, but because around 30% of the general population and an even higher proportion of “high-risk” subjects including diabetics and family members also carry these markers, the specificity of this test is not ideal. The greatest diagnostic utility of this test appears to be its NPV.

Biopsy itself, when used with a strict cut-off requiring villous atrophy, appears to have high specificity, but poor sensitivity. Using lower grade cut-offs clearly improves sensitivity, but because of the wide differential of causes of histological lesions similar to Marsh I to IIIa, the specificity suffers. The use of histomorphometric measures, such as quantification of γδ+ IELs, are likely to allow for the use of lower-grade cut-offs while maintaining reasonable specificity. Ultimately, a trial utilizing multiple diagnostic tests in an attempt to capture as many CD patients in a clinically-relevant population as possible, with a time dimension including a response to a GFD or gluten challenge, is required to fully assess the diagnostic characteristics of biopsy alone. This type of study would be able to characterize the false-positive and false-negative rates if all studied patients are followed forward in time.

The included prevalence studies demonstrated important differences in execution, tests for prevalence assessment, and in patient sampling, and their results also have to be interpreted in the light of some of the limitations that have been identified regarding the diagnostic performance of the tests for CD. Nonetheless, the results of this report suggest that CD is a very common disorder with a prevalence in the general population that is likely close to 1:100 (1%). Several high-risk groups with a prevalence of CD greater than that of the general population have been identified including those suspected of having CD, family members of CD patients, type I diabetics, and those with IDA or low BMD. Additionally, the review identified multiple other high-risk groups such as those with Down Syndrome, short stature, and infertility, to name a few, though their inclusion was beyond the scope of this report. These results would suggest that at the very least, high-risk groups should be screened for CD. If the performance of the noninvasive serological tests can be verified in the relatively “low prevalence” situations in general unselected populations, then population screening may also be advisable, particularly if a greater understanding of the consequences of missing early low-grade CD can be obtained, and the issues of low-compliance with a GFD of asymptomatic screen identified patients can be addressed.

CD is known to be associated with GI lymphoma. The results of this report confirm this strong association, with the limitations indicated in the text. Nonetheless, the report identified SIR for lymphoma that ranged from 4 to 40, and SMR that ranged from 11 to 70. GI lymphoma is believed to arise as a result of chronic antigenic stimulation, which leads to the development of a clonal T-cell population with usually a refractory intermediate stage. We have identified epidemiologic data that supports this notion, and suggests that a diagnostic delay, and in particular diagnosis of CD in adulthood, as apposed to in childhood, is associated with poorer outcomes. Fortunately, several studies suggest that adherence to a GFD reduces the risk of lymphoma in CD patients. These findings underscore the importance of early diagnosis and treatment of CD.

The consequences of testing for, and identifying CD patients, is expected to have a positive impact on patient outcomes be it either from a reduced risk of lymphoma with early diagnosis and treatment of CD or from improvements in nutritional status, BMI, and BMD. The consequences of testing in at-risk and symptomatic patients appears to be more straightforward since these patients appear to be more compliant with a GFD and would be expected to benefit from this intervention. The data is less clear for asymptomatic screen-identified patients, particularly those who are truly silent and/or don't have fully developed villous atrophy since, on the one hand the outcome of such patients has not been extensively studied, and on the other hand, compliance with a GFD appears problematic, particularly for those diagnosed in adulthood.

Finally, no specific interventions have been identified that promote adherence to a GFD, but education of patients and family members about CD and about the intricacies of the GFD through multidisciplinary teams, and participation in local CD societies, has been show to improve compliance. Therefore, the development and evaluation of formal educational interventions in collaboration between healthcare professionals and CD societies would appear to be a means to build on the methods that appear to already improve patient compliance. Monitoring of adherence to a GFD appears to be important, since improvement in histologic grade has been associated with improved BMD, IDA, and nutritional status. The serological markers appear to be adequate for detecting gross dietary indiscretion, and responding to gluten challenge, but unfortunately, they have poor sensitivity for detecting lesser degrees of dietary indiscretion, and have inadequate correlation with histological improvement at least in the short-term. It is true that histological improvement tends to lag behind clinical and serological improvement, especially in adults in whom improvement may never be complete, but even considering this, a negative serological test has been shown to miss patients with persistent villous atrophy. The recognition of persistent villous atrophy appears to be important since improvement beyond this level is associated with the improved outcomes listed above. It should be noted, however, that we could not identify a controlled study that objectively determined the level of histological improvement that would be associated with improved outcomes, and this is an area for future study. Although somewhat controversial, nonetheless, based on this report it would appear that follow-up biopsy, at least 1 year after GFD in adults to document improvement of the histological grade, would be valuable.