# Future Research

This review has allowed us to identify several areas in need of future research. Perhaps the most important of these is a need for the development of a consensus on the definition of CD in the era of advanced serological testing. As discussed in the report, this distinction of what one calls CD has profound implications for each of the requested task order objectives. Do screen-positive patients without villous atrophy have CD. Certainly the preliminary evidence suggests that this is the situation in many cases. However, what is required is a new definition of a gold standard for the diagnosis of CD. This new gold standard may include a combination of serology, biopsy and HLA testing. Such a gold standard, when used in studies with a time dimension (e.g., response to a GFD or gluten challenge; extended follow-up), would help answer some of the uncertainties identified in this report including: the real performance of the serological tests when low-grade lesions are considered CD; the diagnostic performance of biopsy alone; the outcomes of patients with these low-grade lesions; and, those that would be “missed” using current screening strategies. Even in the absence of a new gold standard, we could not identify a well-conducted study of the diagnostic performance of the various serological markers when applied to an average population (i.e., one with a prevalence of CD in keeping with the range identified for average risk), with the entire cohort being investigated equally (i.e., all are biopsied). Such a study would at least be able to shed light on the performance of these tests in average-risk patients, and since all patients are biopsied, the relationship of histology to serology could be further assessed.

On a similar theme, we have identified multiple studies that suggest the importance of histological improvement on a GFD. This is a controversial area since in common clinical practice, clinicians are moving away from routine follow-up biopsy. It seems reasonable to believe that improvement in clinical parameters with loss of serological markers is adequate evidence of response to a GFD. In children, this issue may be less important since histological improvement is much more rapid and complete than in adults, and correlation with serology seems better. However, we have identified multiple studies in adults that suggest poor correlation between serology and improvement of histology on a GFD, and other studies that suggest that serology is useful for detecting gross dietary indiscretion, but not minor occurrences. Therefore, the question that arises is what constitutes adequate improvement on a GFD, and what are the criteria to define this improvement. Based on the lymphoma literature that suggests that this malignancy may arise from chronic antigenic stimulation and immune activation, what are the outcomes of adults with clinical improvement, yet persistent histological abnormalities? Are some histological features, such as reduction of mucosal lymphocytes, more important markers of improvement and possibly prognosis than other features such as villous height?

We feel that clarification of these fundamental questions is necessary for the conduct of future studies in all areas of CD, and in particular studies of the diagnostic tests and the outcomes in CD, since these are so dependent on the definitions discussed above.