# References and Included Studies

1 Marsh M N. Gluten, major histocompatibility complex, and the small intestine: A molecular and immunobiologic approach to the spectrum of gluten sensitivity (‘celiac sprue’). Gastroenterology. 1992;102(1):330-54. [pmid: 1727768].
2 McNeish A S, Harms H K, Rey J, Shmerling D H, Visakorpi J K, Walker-Smith J A. The diagnosis of coeliac disease. A commentary on the current practices of members of the European Society for Paediatric Gastroenterology and Nutrition (ESPGAN). Archives of Disease in Childhood. 1979;54(10):783-6. [pmid: 507902].
3 Oberhuber G, Granditsch G, Vogelsang H. The histopathology of coeliac disease: time for a standardized report scheme for pathologists. European Journal of Gastroenterology & Hepatology. 1999;11(10):1185-94. [pmid: 10524652].
4 Walker-Smith J A, Guandalini S, Schmitz J, Shmerling D H, Visakorpi J K. Revised criteria for diagnosis of coeliac disease. Arch Dis Child. 1990;65(8):909-11. [pmid: 2205160].
5 van de W Y, Kooy Y, van Veelen P, Vader W, Koning F, Pena S. Coeliac disease: it takes three to tango!. Gut. 2000;46(5):734-7. [pmid: 10764722]. [pmcid: 1727918].
6 Papadopoulos G K, Wijmenga C, Koning F. Interplay between genetics and the environment in the development of celiac disease: perspectives for a healthy life. Journal of Clinical Investigation. 2001;108(9):1261-6. [pmid: 11696566]. [pmcid: 209453].
7 Sollid L M, McAdam S N, Molberg O, Quarsten H, Arentz-Hansen H, Louka A S, et al. Genes and environment in celiac disease. Acta Odontologica Scandinavica. 2001;59(3):183-6. [pmid: 11501889].
8 Sollid L M, Markussen G, Ek J, Gjerde H, Vartdal F, Thorsby E. Evidence for a primary association of celiac disease to a particular HLA-DQ alpha/beta heterodimer. Journal of Experimental Medicine. 1989;169(1):345-50. [pmid: 2909659].
9 Ploski R, Ek J, Thorsby E, Sollid L M. On the HLA-DQ(alpha 1*0501, beta 1*0201)-associated susceptibility in celiac disease: a possible gene dosage effect of DQB1*0201. Tissue Antigens. 1993;41(4):173-7. [pmid: 8362409].
10 Ploski R, Ascher H, Sollid L M. HLA genotypes and the increased incidence of coeliac disease in Sweden. Scand J Gastroenterol. 1996;31(11):1092-7. [pmid: 8938902].
11 Holopainen P, Mustalahti K, Uimari P, Collin P, Maki M, Partanen J. Candidate gene regions and genetic heterogeneity in gluten sensitivity. Gut. 2001;48(5):696-701. [pmid: 11302971]. [pmcid: 1728294].
12 Kagnoff M F. Celiac disease pathogenesis: the plot thickens. Gastroenterology. 2002;123(3):939-43. [pmid: 12198718].
13 Feldman M, Friedman LS, Sleisenger MH. Sleisenger and Fordtran's Gastrointestinal and Liver Disease. 7th edition W.B. Saunders; 2003.
14 Fasano A, Catassi C. Current approaches to diagnosis and treatment of celiac disease: an evolving spectrum. Gastroenterology. 2001;120(3):636-51. [pmid: 11179241].
15 Fasano A, Berti I, Gerarduzzi T, Not T, Colletti R B, Drago S, et al. Prevalence of celiac disease in at-risk and not-at-risk groups in the United States: a large multicenter study. Archives of Internal Medicine. 2003;163(3):286-92. [pmid: 12578508].
16 Rostami K, Kerckhaert J, Tiemessen R, von Blomberg B M, Meijer J W, Mulder C J. Sensitivity of antiendomysium and antigliadin antibodies in untreated celiac disease: disappointing in clinical practice. American Journal of Gastroenterology. 1999;94(4):888-94. [pmid: 10201452].
17 Rosenthal D S, Roop D R, Huff C A, Weiss J S, Ellis C N, Hamilton T, et al. Changes in photo-aged human skin following topical application of all-trans retinoic acid. Journal of Investigative Dermatology. 1990;95(5):510-5. [pmid: 1700022].
18 Wahab PJ, Meijer JWR, Goerres MS, Mulder CJJ. Coeliac disease: changing views on gluten-sensitive enteropathy. Scandinavian Journal of Gastroenterology Supplement 2002;(236):60–5.
19 Whiting P, Rutjes AW, Reitsma JB, Bossuyt PM, Kleijnen J. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol 2003;3(1):25. Available: PM:14606960.
20 Wells GA, Shea B, O'Connell D, Peterson J,Welch V, Tugwell P. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. 3rd Symposium on Systematic Reviews: Beyond the Basics, July 2000 in Oxford.2000.
21 Ophthalmology Study Design Worksheet #3 Noncomparative (nonrandomized, noncontrolled) Interventional Case Series. 2004. Ref Type: Internet Communication
22 Moses LE, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: data-analytic approaches and some additional considerations. Stat Med 1993;12(14):1293–316. Available: PM:8210827.
23 Littenberg B, Moses LE. Estimating diagnostic accuracy from multiple conflicting reports: a new meta-analytic method. Med Decis Making 1993;13(4):313–21. Available: PM:8246704.
24 Deeks J. Systematics reviews of evaluations of diagnostic and screening test. Systematic Reviews in Health Care: Meta-analysis in Context. London: BMJ Books, 2001.
25 Deeks J, Altman D, Bradburn J. Statistical methods for examining heterogeneity and combining results from several studies in meta-analysis. Systematic Review in Health Care. Meta-Analysis in Context London: BMJ Books; 2001.
26 Altuntas B, Kansu A, Ensari A, Girgin N. Celiac disease in Turkish short-statured children and the value of antigliadin antibody in diagnosis. Acta Paediatr Jpn. 1998;40(5):457-60. [pmid: 9821706].
27 Ascher H, Hahn-Zoric M, Hanson L A, Kilander A F, Nilsson L A, Tlaskalova H. Value of serologic markers for clinical diagnosis and population studies of coeliac disease. Scandinavian Journal of Gastroenterology. 1996;31(1):61-7. [pmid: 8927942].
28 Ascher H, Lanner A, Kristiansson B. A new laboratory kit for anti-gliadin IgA at diagnosis and follow-up of childhood celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1990;10(4):443-50. [pmid: 2358975].
29 Bahia M, Rabello A, Brasileiro F G, Penna F J. Serum antigliadin antibody levels as a screening criterion before jejunal biopsy indication for celiac disease in a developing country. Brazilian Journal of Medical and Biological Research = Revista Brasileira De Pesquisas Medicas E Biologicas / Sociedade Brasileira De Biofisica Et Al. 2001;34(11):1415-20. [pmid: 11668350].
30 Bardella M T, Trovato C, Cesana B M, Pagliari C, Gebbia C, Peracchi M. Serological markers for coeliac disease: is it time to change?. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2001;33(5):426-31. [pmid: 11529655].
31 Berger R, Schmidt G. Evaluation of six anti-gliadin antibody assays. Journal of Immunological Methods. 1996;191(1):77-86. [pmid: 8642204].
32 Biagi F, Pezzimenti D, Campanella J, Vadacca G B, Corazza G R. Endomysial and tissue transglutaminase antibodies in coeliac sera: a comparison not influenced by previous serological testing. Scandinavian Journal of Gastroenterology. 2001;36(9):955-8. [pmid: 11521986].
33 Bode S, Gudmand-Hoyer E. Evaluation of the gliadin antibody test for diagnosing coeliac disease. Scandinavian Journal of Gastroenterology. 1994;29(2):148-52. [pmid: 8171283].
34 Bode S, Weile B, Krasilnikoff P A, Gudmand-Hoyer E. The diagnostic value of the gliadin antibody test in celiac disease in children: a prospective study. Journal of Pediatric Gastroenterology and Nutrition. 1993;17(3):260-4. [pmid: 8271124].
35 Bonamico M, Tiberti C, Picarelli A, Mariani P, Rossi D, Cipolletta E, et al. Radioimmunoassay to detect antitransglutaminase autoantibodies is the most sensitive and specific screening method for celiac disease. American Journal of Gastroenterology. 2001;96(5):1536-40. [pmid: 11374695].
36 Bottaro G, Volta U, Spina M, Rotolo N, Sciacca A, Musumeci S. Antibody pattern in childhood celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1997;24(5):559-62. [pmid: 9161952].
37 Carroccio A, Iacono G, D'Amico D, Cavataio F, Teresi S, Caruso C, et al. Production of anti-endomysial antibodies in cultured duodenal mucosa: usefulness in coeliac disease diagnosis. Scandinavian Journal of Gastroenterology. 2002;37(1):32-8. [pmid: 11843032].
38 Carroccio A, Iacono G, Montalto G, Cavataio F, Soresi M, Kazmierska I, et al. Immunologic and absorptive tests in celiac disease: can they replace intestinal biopsies?. Scandinavian Journal of Gastroenterology. 1993;28(8):673-6. [pmid: 8210980].
39 Carroccio A, Vitale G, Di Prima L, Chifari N, Napoli S, La Russa C, et al. Comparison of anti-transglutaminase ELISAs and an anti-endomysial antibody assay in the diagnosis of celiac disease: a prospective study. Clinical Chemistry. 2002;48(9):1546-50. [pmid: 12194932].
40 Cataldo F, Lio D, Marino V, Picarelli A, Ventura A, Corazza G R. IgG(1) antiendomysium and IgG antitissue transglutaminase (anti-tTG) antibodies in coeliac patients with selective IgA deficiency. Working Groups on Celiac Disease of SIGEP and Club del Tenue. Gut. 2000;47(3):366-9. [pmid: 10940273]. [pmcid: 1728054].
41 Chan A W, Butzner J D, McKenna R, Fritzler M J. Tissue transglutaminase enzyme-linked immunosorbent assay as a screening test for celiac disease in pediatric patients. Pediatrics. 2001;107(1):E8. [pmid: 11134472].
42 Chartrand L J, Agulnik J, Vanounou T, Russo P A, Baehler P, Seidman E G. Effectiveness of antigliadin antibodies as a screening test for celiac disease in children. Cmaj - Canadian Medical Association Journal = Journal De L'association Medicale Canadienne. 1997;157(5):527-33.
43 Chirdo F G, Rumbo M, Carabajal P, Castagnino N, Mavromatopulos E, Cirincione V, et al. Analysis of anti-gliadin antibodies by immunoblot analysis and enzyme-linked immunosorbent assay using gliadin fractions as antigens. Journal of Pediatric Gastroenterology and Nutrition. 1999;29(2):171-7. [pmid: 10435654].
44 Chirdo F G, Rumbo M, Carabajal P, Mavromatopulos E, Castagnino N, Anon M C, et al. Determination of anti-omega-gliadin antibodies in serologic tests for coeliac disease. Scandinavian Journal of Gastroenterology. 2000;35(5):508-16. [pmid: 10868454].
45 Dahele A, Aldhous M C, Humphreys K, Ghosh S. Serum IgA tissue transglutaminase antibodies in coeliac disease and other gastrointestinal diseases. Q J Med. 2001;94(4):195-205.
46 Di Leo M, Weisz G, Ansaldi B N. Serum and salivary antiendomysium antibodies in the screening of coeliac disease. Panminerva Medica. 1999;41(1):68-71. [pmid: 10230262].
47 Dickey W, McMillan S A, Hughes D F. Sensitivity of serum tissue transglutaminase antibodies for endomysial antibody positive and negative coeliac disease. Scandinavian Journal of Gastroenterology. 2001;36(5):511-4. [pmid: 11346205].
48 Falth-Magnusson K, Jansson G, Stenhammar L, Magnusson K E. Serum food antibodies analyzed by enzyme-linked immunosorbent assay (ELISA) and diffusion-in-gel (DIG)-ELISA methods in children with and without celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1994;18(1):56-62. [pmid: 8126619].
49 Gillett H R, Freeman H J. Comparison of IgA endomysium antibody and IgA tissue transglutaminase antibody in celiac disease. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterology. 2000;14(8):668-71.
50 Gonczi J, Skerritt J H, Mitchell J D. A reliable screening test for coeliac disease: enzyme-linked immunosorbent assay to detect anti-gliadin antibodies in serum. Australian and New Zealand Journal of Medicine. 1991;21(5):723-31. [pmid: 1759921].
51 Hallstrom O. Comparison of IgA-class reticulin and endomysium antibodies in coeliac disease and dermatitis herpetiformis. Gut. 1989;30(9):1225-32. [pmid: 2806989]. [pmcid: 1434235].
52 Hansson T, Dahlbom I, Hall J, Holtz A, Elfman L, Dannaeus A, et al. Antibody reactivity against human and guinea pig tissue transglutaminase in children with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 2000;30(4):379-84. [pmid: 10776947].
53 Iltanen S, Rantala I, Laippala P, Holm K, Partanen J, Maki M. Expression of HSP-65 in jejunal epithelial cells in patients clinically suspected of coeliac disease. Autoimmunity. 1999;31(2):125-32. [pmid: 10680751].
54 Kaukinen K, Turjanmaa K, Maki M, Partanen J, Venalainen R, Reunala T, et al. Intolerance to cereals is not specific for coeliac disease. Scandinavian Journal of Gastroenterology. 2000;35(9):942-6. [pmid: 11063153].
55 Kolho K L, Savilahti E. IgA endomysium antibodies on human umbilical cord: an excellent diagnostic tool for celiac disease in childhood. Journal of Pediatric Gastroenterology and Nutrition. 1997;24(5):563-7. [pmid: 9161953].
56 Kumar V, Lerner A, Valeski J E, Beutner E H, Chorzelski T P, Rossi T. Endomysial antibodies in the diagnosis of celiac disease and the effect of gluten on antibody titers. Immunological Investigations. 1989;18(14):533-44. [pmid: 2499536].
57 Ladinser B, Rossipal E, Pittschieler K. Endomysium antibodies in coeliac disease: an improved method. Gut. 1994;35(6):776-8. [pmid: 8020804]. [pmcid: 1374877].
58 Lerner A, Kumar V, Iancu T C. Immunological diagnosis of childhood coeliac disease: comparison between antigliadin, antireticulin and antiendomysial antibodies. Clinical and Experimental Immunology. 1994;95(1):78-82. [pmid: 8287612]. [pmcid: 1534627].
59 Lindberg T, Nilsson L A, Borulf S, Cavell B, Fallstrom S P, Jansson U, et al. Serum IgA and IgG gliadin antibodies and small intestinal mucosal damage in children. Journal of Pediatric Gastroenterology and Nutrition. 1985;4(6):917-22. [pmid: 4067780].
60 Lindquist B L, Rogozinski T, Moi H, Danielsson D, Olcen P. Endomysium and gliadin IgA antibodies in children with coeliac disease. Scandinavian Journal of Gastroenterology. 1994;29(5):452-6. [pmid: 8036461].
61 Lock R J, Pitcher M C, Unsworth D J. IgA anti-tissue transglutaminase as a diagnostic marker of gluten sensitive enteropathy. Journal of Clinical Pathology. 1999;52(4):274-7. [pmid: 10474519]. [pmcid: 501332].
62 Maki M, Holm K, Lipsanen V, Hallstrom O, Viander M, Collin P, et al. Serological markers and HLA genes among healthy first-degree relatives of patients with coeliac disease. Lancet. 1991;338(8779):1350-3. [pmid: 1682735].
63 McMillan S A, Haughton D J, Biggart J D, Edgar J D, Porter K G, McNeill T A. Predictive value for coeliac disease of antibodies to gliadin, endomysium, and jejunum in patients attending for jejunal biopsy. Bmj (Clinical Research Ed ). 1991;303(6811):1163-5. [pmid: 1747612].
64 Meini A, Pillan N M, Villanacci V, Monafo V, Ugazio A G, Plebani A. Prevalence and diagnosis of celiac disease in IgA-deficient children. Annals of Allergy, Asthma & Immunology - Official Publication of the American College of Allergy, Asthma, & Immunology. 1996;77(4):333-6. [pmid: 8885812].
65 Pacht A, Sinai N, Hornstein L, Kumar V, Ish-Shalom N, Lerner A. The diagnostic reliability of anti-endomysial antibody in celiac disease: the north Israel experience. Israel Journal of Medical Sciences. 1995;31(4):218-20. [pmid: 7721558].
66 Picarelli A, Sabbatella L, Di Tola M, Gabrielli F, Greco R, Di Cello T, et al. Celiac disease diagnosis in misdiagnosed children. Pediatric Research. 2000;48(5):590-2. [pmid: 11044476].
67 Poddar U, Thapa B R, Nain C K, Prasad A, Singh K. Celiac disease in India: are they true cases of celiac disease?. Journal of Pediatric Gastroenterology and Nutrition. 2002;35(4):508-12. [pmid: 12394375].
68 Rich E J, Christie D L. Anti-gliadin antibody panel and xylose absorption test in screening for celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1990;10(2):174-8. [pmid: 2182821].
69 Russo P A, Chartrand L J, Seidman E. Comparative analysis of serologic screening tests for the initial diagnosis of celiac disease. Pediatrics. 1999;104(1 Pt 1):75-8. [pmid: 10390263].
70 Salmaso C, Ocmant A, Pesce G, Altrinetti V, Montagna P, Descalzi D, et al. Comparison of ELISA for tissue transglutaminase autoantibodies with antiendomysium antibodies in pediatric and adult patients with celiac disease. Allergy. 2001;56(6):544-7. [pmid: 11421901].
71 Sategna-Guidetti C, Grosso S, Bruno M, Grosso S B. Comparison of serum anti-gliadin, anti-endomysium, and anti-jejunum antibodies in adult celiac sprue. Journal of Clinical Gastroenterology. 1995;20(1):17-21. [pmid: 7884170].
72 Sblattero D, Berti I, Trevisiol C, Marzari R, Tommasini A, Bradbury A, et al. Human recombinant tissue transglutaminase ELISA: an innovative diagnostic assay for celiac disease. American Journal of Gastroenterology. 2000;95(5):1253-7. [pmid: 10811336].
73 Sulkanen S, Collin P, Laurila K, Maki M. IgA- and IgG-class antihuman umbilical cord antibody tests in adult coeliac disease. Scandinavian Journal of Gastroenterology. 1998;33(3):251-4. [pmid: 9548617].
74 Sulkanen S, Halttunen T, Laurila K, Kolho K L, Korponay-Szabo I R, Sarnesto A, et al. Tissue transglutaminase autoantibody enzyme-linked immunosorbent assay in detecting celiac disease. Gastroenterology. 1998;115(6):1322-8. [pmid: 9834257].
75 Tesei N, Sugai E, Vazquez H, Smecuol E, Niveloni S, Mazure R, et al. Antibodies to human recombinant tissue transglutaminase may detect coeliac disease patients undiagnosed by endomysial antibodies. Alimentary Pharmacology & Therapeutics. 2003;17(11):1415-23. [pmid: 12786636].
76 Troncone R, Maurano F, Rossi M, Micillo M, Greco L, Auricchio R, et al. IgA antibodies to tissue transglutaminase: An effective diagnostic test for celiac disease. Journal of Pediatrics. 1999;134(2):166-71. [pmid: 9931524].
77 Valdimarsson T, Franzen L, Grodzinsky E, Skogh T, Strom M. Is small bowel biopsy necessary in adults with suspected celiac disease and IgA anti-endomysium antibodies? 100% positive predictive value for celiac disease in adults. Digestive Diseases and Sciences. 1996;41(1):83-7. [pmid: 8565771].
78 Valentini R A, Andreani M L, Corazza G R, Gasbarrini G. IgA endomysium antibody: a valuable tool in the screening of coeliac disease but not its follow-up. Italian Journal of Gastroenterology. 1994;26(6):279-82. [pmid: 7949263].
79 Vitoria J C, Arrieta A, Ortiz L, Ayesta A. Antibodies to human tissue transglutaminase for the diagnosis of celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 2001;33(3):349-50. [pmid: 11593137].
80 Vogelsang H, Genser D, Wyatt J, Lochs H, Ferenci P, Granditsch G, et al. Screening for celiac disease: a prospective study on the value of noninvasive tests. American Journal of Gastroenterology. 1995;90(3):394-8. [pmid: 7872276].
81 Volta U, Molinaro N, De Franceschi L, Fratangelo D, Bianchi F B. IgA anti-endomysial antibodies on human umbilical cord tissue for celiac disease screening. Save both money and monkeys. Digestive Diseases and Sciences. 1995;40(9):1902-5. [pmid: 7555440].
82 Whelan A, Willoughby R, Weir D. Human umbilical vein endothelial cells: a new easily available source of endomysial antigens. European Journal of Gastroenterology & Hepatology. 1996;8(10):961-6. [pmid: 8930559].
83 Wolters V, Vooijs-Moulaert A, Burger H, Brooimans R, De Schryver J, Rijkers G, et al. Human tissue transglutaminase enzyme linked immunosorbent assay outperforms both the guinea pig based tissue transglutaminase assay and anti-endomysium antibodies when screening for coeliac disease. European Journal of Pediatrics. 2002;161(5):284-7. [pmid: 12012226].
84 Di Leo M, Weisz G, Ansaldi B N. Serum and salivary antiendomysium antibodies in the screening of coeliac disease. Panminerva Medica. 1999;41(1):68-71. [pmid: 10230262].
85 Artan R. Antigliadin antibody measurement as a screening test for childhood coeliac disease. Int Med J. 1998;5(3):209-12.
86 Dahele A, Kingstone K, Bode J, Anderson D, Ghosh S. Anti-endomysial antibody negative celiac disease: does additional serological testing help?. Digestive Diseases and Sciences. 2001;46(1):214-21. [pmid: 11270789].
87 Brandborg L L, Goldberg S B, Breidenbach W C. Human coccidiosis--a possible cause of malabsorption. New England Journal of Medicine. 1970;283(24):1306-13. [pmid: 5478452].
88 Hazama H, Omagari K, Masuda J, Ohba K, Kinoshita H, Matsuo I, et al. Automated enzymatic mitochondrial antibody assay for the diagnosis of primary biliary cirrhosis: applications of a routine diagnostic tool for the detection of antimitochondrial antibodies. Journal of Gastroenterology and Hepatology. 2002;17(3):316-23. [pmid: 11982703].
89 Cheli R, Giacosa A. Inflammatory cell count and identification in specific duodenitis. (Celiac disease, Whipple's disease and Crohn's disease). Comparison with jejunal findings. Endoscopy. 1977;9(3):147-51. [pmid: 71989].
90 Talbot H S. A report on sexual function in paraplegics. J Urol. 1949;61:265-70. [pmid: 18111847].
91 Fernandez-Arquero M, Polanco I, Escobar H, Figueredo M A, de la Concha E G, Clerici-Larradet N, et al. HLA-DQ alleles and susceptibility to celiac disease in Spanish children. Tissue Antigens. 1995;45(2):145-7. [pmid: 7792763].
92 Palavecino E A, Mota A H, Awad J, DeRosa S, Herrera M, Chertkoff L, et al. HLA and celiac disease in Argentina: involvement of the DQ subregion. Disease Markers. 1990;8(1):5-10. [pmid: 2311351].
93 Spurkland A, Ingvarsson G, Falk E S, Knutsen I, Sollid L M, Thorsby E. Dermatitis herpetiformis and celiac disease are both primarily associated with the HLA-DQ (alpha 1*0501, beta 1*02) or the HLA-DQ (alpha 1*03, beta 1*0302) heterodimers. Tissue Antigens. 1997;49(1):29-34. [pmid: 9027962].
94 Hall M A, Lanchbury J S, Lee J S, Welsh K I, Ciclitira P J. HLA-DQ2 second-domain polymorphisms may explain increased trans-associated risk in celiac disease and dermatitis herpetiformis. Human Immunology. 1993;38(4):284-92. [pmid: 8138424].
95 Spurkland A, Sollid L M, Ronningen K S, Bosnes V, Ek J, Vartdal F, et al. Susceptibility to develop celiac disease is primarily associated with HLA-DQ alleles. Human Immunology. 1990;29(3):157-65. [pmid: 1980918].
96 Bao F, Yu L, Babu S, Wang T, Hoffenberg E J, Rewers M, et al. One third of HLA DQ2 homozygous patients with type 1 diabetes express celiac disease-associated transglutaminase autoantibodies. Journal of Autoimmunity. 1999;13(1):143-8. [pmid: 10441179].
97 Martin-Villa J M, Lopez-Suarez J C, Perez-Blas M, Martinez-Laso J, Ferre-Lopez S, Garcia-Torre C, et al. Coeliac- and enteropathy-associated autoantibodies in Spanish insulin-dependent diabetes mellitus patients and their relation to HLA antigens. Journal of Diabetes and Its Complications. 2001;15(1):38-43. [pmid: 11259925].
98 Kaukinen K, Partanen J, Maki M, Collin P. HLA-DQ typing in the diagnosis of celiac disease. American Journal of Gastroenterology. 2002;97(3):695-9. [pmid: 11922565].
99 Saukkonen T, Ilonen J, Akerblom H K, Savilahti E. Prevalence of coeliac disease in siblings of patients with Type I diabetes is related to the prevalence of DQB1*02 allele. Diabetologia. 2001;44(8):1051-3. [pmid: 11484084].
100 Congia M, Frau F, Lampis R, Frau R, Mele R, Cucca F, et al. A high frequency of the A30, B18, DR3, DRw52, DQw2 extended haplotype in Sardinian celiac disease patients: further evidence that disease susceptibility is conferred by DQ A1*0501, B1*0201. Tissue Antigens. 1992;39(2):78-83. [pmid: 1349446].
101 Herrera M, Theiler G, Augustovski F, Chertkoff L, Fainboim L, DeRosa S, et al. Molecular characterization of HLA class II genes in celiac disease patients of Latin American Caucasian origin. Tissue Antigens. 1994;43(2):83-7. [pmid: 8016846].
102 Petronzelli F, Ferrante P, Triglione P, Bonamico M, Mazzilli M C. Oligotyping of celiac multiplex families with the 11th International Histocompatibility Workshop reagents. Tissue Antigens. 1991;38(5):238-9. [pmid: 1780848].
103 Mantovani V, Corazza G R, Angelini G, Delfino L, Frisoni M, Mirri P, et al. Molecular analysis of HLA-DQ A alleles in coeliac disease lack of a unique disease-associated sequence. Clinical and Experimental Immunology. 1991;83(1):74-8. [pmid: 1671007]. [pmcid: 1535481].
104 Agardh D, Nilsson A, Carlsson A, Kockum I, Lernmark A, Ivarsson S A. Tissue transglutaminase autoantibodies and human leucocyte antigen in Down Syndrome patients with coeliac disease. Acta Paediatrica (Oslo, Norway - 1992). 2002;91(1):34-8. [pmid: 11883815].
105 Bonamico M, Mazzilli M C, Morellini M, Vania A, Carpino F, Nicotra M R, et al. Expression of class II MHC antigens in the intestinal epithelium of pediatric celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1989;9(3):269-75. [pmid: 2693680].
106 Bonamico M, Morellini M, Mariani P, Triglione P, Trabace S, Lulli P, et al. HLA antigens and antigliadin antibodies in coeliac disease. Dis Markers. 1991;9(6):313-7. [pmid: 1823310].
107 Brett P M, Yiannakou J Y, Morris M A, Vaughan R, Curtis D, Ciclitira P J. Common HLA alleles, rather than rare mutants, confer susceptibility to coeliac disease. Annals of Human Genetics. 1999;63(Pt 3):217-25. [pmid: 10738534].
108 Collin P, Syrjanen J, Partanen J, Pasternack A, Kaukinen K, Mustonen J. Celiac disease and HLA DQ in patients with IgA nephropathy. American Journal of Gastroenterology. 2002;97(10):2572-6. [pmid: 12385441].
109 Csizmadia C G, Mearin M L, Oren A, Kromhout A, Crusius J B, von Blomberg B M, et al. Accuracy and cost-effectiveness of a new strategy to screen for celiac disease in children with Down syndrome. Journal of Pediatrics. 2000;137(6):756-61. [pmid: 11113830].
110 Falchuk Z M, Katz A J, Shwachman H, Rogentine G N, Strober W. Gluten-sensitive enteropathy: genetic analysis and organ culture study in 35 families. Scandinavian Journal of Gastroenterology. 1978;13(7):839-43. [pmid: 82994].
111 Fedrick J A, Pandey J P, Verkasalo M, Teppo A M, Fudenberg H H. Immunoglobulin allotypes and the immune response to wheat gliadin in a Finnish population with celiac disease. Experimental and Clinical Immunogenetics. 1985;2(4):185-90. [pmid: 3917148].
112 Hansson T, Anneren G, Sjoberg O, Klareskog L, Dannaeus A. Celiac disease in relation to immunologic serum markers, trace elements, and HLA-DR and DQ antigens in Swedish children with Down syndrome. J Pediatr Gastroenterol Nutr. 1999;29(3):286-92. [pmid: 10467993].
113 Lampasona V, Bonfanti R, Bazzigaluppi E, Venerando A, Chiumello G, Bosi E, et al. Antibodies to tissue transglutaminase C in type I diabetes. Diabetologia. 1999;42(10):1195-8. [pmid: 10525659].
114 Lorini R, Scotta M S, Cortona L, Avanzini M A, Vitali L, De Giacomo C, et al. Celiac disease and type I (insulin-dependent) diabetes mellitus in childhood: follow-up study. Journal of Diabetes and Its Complications. 1996;10(3):154-9. [pmid: 8807465].
115 Lundin K E, Sollid L M, Anthonsen D, Noren O, Molberg O, Thorsby E, et al. Heterogeneous reactivity patterns of HLA-DQ-restricted, small intestinal T-cell clones from patients with celiac disease. Gastroenterology. 1997;112(3):752-9. [pmid: 9041236].
116 Mearin M L, Koninckx C R, Biemond I, Polanco I, Pena A S. Influence of genetic factors on the serum levels of antigliadin antibodies in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1984;3(3):373-7. [pmid: 6588183].
117 Silva E M, Fernandes M I, Galvao L C, Sawamura R, Donadi E A. Human leukocyte antigen class II alleles in white Brazilian patients with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 2000;31(4):391-4. [pmid: 11045836].
118 Stern M. Comparative evaluation of serologic tests for celiac disease: a European initiative toward standardization. Journal of Pediatric Gastroenterology and Nutrition. 2000;31(5):513-9. [pmid: 11144436].
119 Bevan S, Popat S, Braegger C P, Busch A, O'Donoghue D, Falth-Magnusson K, et al. Contribution of the MHC region to the familial risk of coeliac disease. Journal of Medical Genetics. 1999;36(9):687-90. [pmid: 10507725].
120 Catassi C, Doloretta M M, Ratsch I M, De Virgiliis S, Cucca F. The distribution of DQ genes in the Saharawi population provides only a partial explanation for the high celiac disease prevalence. Tissue Antigens. 2001;58(6):402-6. [pmid: 11929591].
121 Clot F, Gianfrani C, Babron M C, Bouguerra F, Southwood S, Kagnoff M F, et al. HLA-DR53 molecules are associated with susceptibility to celiac disease and selectively bind gliadin-derived peptides. Immunogenetics. 1999;49(9):800-7. [pmid: 10398807].
122 Holm K, Savilahti E, Koskimies S, Lipsanen V, Maki M. Immunohistochemical changes in the jejunum in first degree relatives of patients with coeliac disease and the coeliac disease marker DQ genes. HLA class II antigen expression, interleukin-2 receptor positive cells and dividing crypt cells. Gut. 1994;35(1):55-60. [pmid: 8307450]. [pmcid: 1374632].
123 Karell K, Holopainen P, Mustalahti K, Collin P, Maki M, Partanen J. Not all HLA DR3 DQ2 haplotypes confer equal susceptibility to coeliac disease: transmission analysis in families. Scand J Gastroenterol. 2002;37(1):56-61. [pmid: 11843036].
124 Meddeb-Garnaoui A, Zeliszewski D, Mougenot J F, Djilali-Saiah I, Caillat-Zucman S, Dormoy A, et al. Reevaluation of the relative risk for susceptibility to celiac disease of HLA-DRB1, -DQA1, -DQB1, -DPB1, and -TAP2 alleles in a French population. Human Immunology. 1995;43(3):190-9. [pmid: 7558936].
125 Ruiz M Y, Olivares J L. Three-loci HLA haplotypes in Spanish celiac children and healthy subjects: estimation of linkage disequilibrium and haplotype frequencies. Am J Gastroenterol. 2001;96(5):1455-9. [pmid: 11374682].
126 Volta U, Bellentani S, Bianchi F B, Brandi G, De Franceschi L, Miglioli L, et al. High prevalence of celiac disease in Italian general population. Dig Dis Sci. 2001;46(7):1500-5. [pmid: 11478502].
127 O'Driscoll B R, Stevens F M, O'Gorman T A, Finnegan P, McWeeney J J, Little M P, et al. HLA type of patients with coeliac disease and malignancy in the west of Ireland. Gut. 1982;23(8):662-5. [pmid: 7095561]. [pmcid: 1419133].
128 Hoffenberg E J, MacKenzie T, Barriga K J, Eisenbarth G S, Bao F, Haas J E, et al. A prospective study of the incidence of childhood celiac disease. J Pediatr. 2003;143(3):308-14. [pmid: 14517510].
129 Holm K H. Correlation of HLA-DR alleles to jejunal mucosal morphology in healthy first-degree relatives of coeliac disease patients. Eur J Gastroenterol Hepatol. 1993;5(1):35-9.
130 Louka A S, Moodie S J, Karell K, Bolognesi E, Ascher H, Greco L, et al. A collaborative European search for non-DQA1 *05-DQB1 *02 Celiac disease loci on HLA-Dr3 haplotypes: Analysis of transmission from homozygous parents. Hum Immunol. 2003;64(3):350-8. [pmid: 12590980].
131 Agrawal S, Gupta A, Yachha S K, Muller-Myhsok B, Mehrotra P, Agarwal S S. Association of human leucocyte-DR and DQ antigens in coeliac disease: a family study. Journal of Gastroenterology and Hepatology. 2000;15(7):771-4. [pmid: 10937683].
132 Louka A S, Lie B A, Talseth B, Ascher H, Ek J, Gudjonsdottir A H, et al. Coeliac disease patients carry conserved HLA-DR3-DQ2 haplotypes revealed by association of TNF alleles. Immunogenetics. 2003;55(5):339-43. [pmid: 12845502].
133 Van Belzen M J, Meijer Jos W R, Sandkuijl L A, Bardoel Alfons F J, Mulder Chris J J, Pearson P L, et al. A major non-HLA locus in celiac disease maps to chromosome 19. Gastroenterology. 2003;125(4):1032-41. [pmid: 14517787].
134 Castro M, Crino A, Papadatou B, Purpura M, Giannotti A, Ferretti F, et al. Down Syndrome and celiac disease: the prevalence of high IgA-antigliadin antibodies and HLA-DR and DQ antigens in trisomy 21. Journal of Pediatric Gastroenterology and Nutrition. 1993;16(3):265-8. [pmid: 8492253].
135 Fine K D, Do K, Schulte K, Ogunji F, Guerra R, Osowski L, et al. High prevalence of celiac sprue-like HLA-DQ genes and enteropathy in patients with the microscopic colitis syndrome. American Journal of Gastroenterology. 2000;95(8):1974-82. [pmid: 10950045].
136 Iltanen S, Holm K, Partanen J, Laippala P, Maki M. Increased density of jejunal gammadelta+ T cells in patients having normal mucosa--marker of operative autoimmune mechanisms?. Autoimmunity. 1999;29(3):179-87. [pmid: 10680751].
137 Perez-Bravo F, Araya M, Mondragon A, Rios G, Alarcon T, Roessler J L, et al. Genetic differences in HLA-DQA1* and DQB1* allelic distributions between celiac and control children in Santiago, Chile. Human Immunology. 1999;60(3):262-7. [pmid: 10321965].
138 Arranz E, Telleria J J, Sanz A, Martin J F, Alonso M, Calvo C, et al. HLA-DQA1*0501 and DQB1*02 homozygosity and disease susceptibility in Spanish coeliac patients. Experimental and Clinical Immunogenetics. 1997;14(4):286-90. [pmid: 9523165].
139 Boy M F, La Nasa G, Balestrieri A, Cherchi M V, Usai P. Distribution of HLA-DPB1, -DQB1 -DQA1 alleles among Sardinian celiac patients. Disease Markers. 1995;12(3):199-204. [pmid: 8590546].
140 Djilali-Saiah I, Caillat-Zucman S, Schmitz J, Chaves-Vieira M L, Bach J F. Polymorphism of antigen processing (TAP, LMP) and HLA class II genes in celiac disease. Human Immunology. 1994;40(1):8-16. [pmid: 8045794].
141 Djilali-Saiah I, Schmitz J, Harfouch-Hammoud E, Mougenot J F, Bach J F, Caillat-Zucman S. CTLA-4 gene polymorphism is associated with predisposition to coeliac disease. Gut. 1998;43(2):187-9. [pmid: 10189842]. [pmcid: 1727221].
142 Erkan T, Kutlu T, Yilmaz E, Cullu F, Tumay G T. Human leukocyte antigens in Turkish pediatric celiac patients. Turkish Journal of Pediatrics. 1999;41(2):181-8. [pmid: 10770656].
143 Fernandez-Arquero M, Figueredo M A, Maluenda C, de la Concha E G. HLA-linked genes acting as additive susceptibility factors in celiac disease. Human Immunology. 1995;42(4):295-300. [pmid: 7558913].
144 Ferrante P, Petronzelli F, Mariani P, Bonamico M, Mazzilli M C. Oligotyping of Italian celiac patients with the 11th International Histocompatibility Workshop reagents. Tissue Antigens. 1992;39(1):38-9. [pmid: 1542877].
145 Mazzilli M C, Ferrante P, Mariani P, Martone E, Petronzelli F, Triglione P, et al. A study of Italian pediatric celiac disease patients confirms that the primary HLA association is to the DQ(alpha 1*0501, beta 1*0201) heterodimer. Human Immunology. 1992;33(2):133-9. [pmid: 1563982].
146 Michalski J P, McCombs C C, Arai T, Elston R C, Cao T, McCarthy C F, et al. HLA-DR, DQ genotypes of celiac disease patients and healthy subjects from the West of Ireland. Tissue Antigens. 1996;47(2):127-33. [pmid: 8851726].
147 Ruiz del Prado M Y, Olivares Lopez J L, Lazaro A A, Lasierra Diaz M P. HLA system. Phenotypic and gene frequencies in celiac and healthy subjects from the same geographical area. Revista Espanola De Enfermedades Digestivas - Organo Oficial De La Sociedad Espanola De Patologia Digestiva. 2001;93(2):106-13. [pmid: 11471223].
148 Tighe M R, Hall M A, Ashkenazi A, Siegler E, Lanchbury J S, Ciclitira P J. Celiac disease among Ashkenazi Jews from Israel. A study of the HLA class II alleles and their associations with disease susceptibility. Human Immunology. 1993;38(4):270-6. [pmid: 8138422].
149 Tighe M R, Hall M A, Barbado M, Cardi E, Welsh K I, Ciclitira P J. HLA class II alleles associated with celiac disease susceptibility in a southern European population. Tissue Antigens. 1992;40(2):90-7. [pmid: 1357780].
150 Tuysuz B, Dursun A, Kutlu T, Sokucu S, Cine N, Suoglu O, et al. HLA-DQ alleles in patients with celiac disease in Turkey. Tissue Antigens. 2001;57(6):540-2. [pmid: 11556984].
151 Howell W M, Leung S T, Jones D B, Nakshabendi I, Hall M A, Lanchbury J S, et al. HLA-DRB, -DQA, and -DQB polymorphism in celiac disease and enteropathy-associated T-cell lymphoma. Common features and additional risk factors for malignancy. Hum Immunol. 1995;43(1):29-37. [pmid: 7558926].
152 Sacchetti L, Calcagno G, Ferrajolo A, Sarrantonio C, Troncone R, Micillo M, et al. Discrimination between celiac and other gastrointestinal disorders in childhood by rapid human lymphocyte antigen typing. Clinical Chemistry. 1998;44(8 Pt 1):1755-7. [pmid: 9702970].
153 Pettersson A, Sjoberg K, Lernmark A, Eriksson S. HLA genotypes in coeliac disease and healthy individuals carrying gliadin antibodies. Eur J Gastroenterol Hepatol. 1993;5(6):445-50.
154 Arnason A, Skaftadottir I, Sigmundsson J, Mooney E, Bjornsson J, Cariglia N, et al. The association between coeliac disease, dermatitis herpetiformis and certain HLA-antigens in Icelanders. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1994;21(6):457-60. [pmid: 9098455].
155 Balas A, Vicario J L, Zambrano A, Acuna D, Garcia-Novo D. Absolute linkage of celiac disease and dermatitis herpetiformis to HLA-DQ. Tissue Antigens. 1997;50(1):52-6. [pmid: 9243756].
156 Colonna M, Mantovani W, Corazza G R, Barboni P, Gasbarrini G, Ferrara G B, et al. Reassessment of HLA association with celiac disease in special reference to the DP association. Human Immunology. 1990;29(4):263-74. [pmid: 2286538].
157 Congia M, Cucca F, Frau F, Lampis R, Melis L, Clemente M G, et al. A gene dosage effect of the DQA1*0501/DQB1*0201 allelic combination influences the clinical heterogeneity of celiac disease. Human Immunology. 1994;40(2):138-42. [pmid: 7928444].
158 Lio D, Bonanno C T, D'Anna C, De Luca S, Gervasi F, Cavataio F, et al. Gluten stimulation induces an in vitro expansion of peripheral blood T gamma delta cells from HLA-DQ2-positive subjects of families of patients with celiac disease. Experimental and Clinical Immunogenetics. 1998;15(1):46-55. [pmid: 9619399].
159 Tumer L, Altuntas B, Hasanoglu A, Soylemezoglu O, Arinsoy T. Pattern of human leukocyte antigens in Turkish children with celiac disease. Pediatrics International - Official Journal of the Japan Pediatric Society. 2000;42(6):678-81. [pmid: 11192527].
160 Book L, Hart A, Black J, Feolo M, Zone J J, Neuhausen S L. Prevalence and clinical characteristics of celiac disease in Downs syndrome in a US study. American Journal of Medical Genetics. 2001;98(1):70-4. [pmid: 11426458].
161 Farre C, Humbert P, Vilar P, Varea V, Aldeguer X, Carnicer J, et al. Serological markers and HLA-DQ2 haplotype among first-degree relatives of celiac patients. Catalonian Coeliac Disease Study Group. Digestive Diseases and Sciences. 1999;44(11):2344-9. [pmid: 10573385].
162 Iltanen S, Collin P, Korpela M, Holm K, Partanen J, Polvi A, et al. Celiac disease and markers of celiac disease latency in patients with primary Sjogren's syndrome. American Journal of Gastroenterology. 1999;94(4):1042-6. [pmid: 10201480].
163 Kaur G, Sarkar N, Bhatnagar S, Kumar S, Rapthap C C, Bhan M K, et al. Pediatric celiac disease in India is associated with multiple DR3-DQ2 haplotypes. Human Immunology. 2002;63(8):677-82. [pmid: 12121676].
164 Neuhausen S L, Weizman Z, Camp N J, Elbedour K, Sheffield V C, Zone J J, et al. HLA DQA1-DQB1 genotypes in Bedouin families with celiac disease. Human Immunology. 2002;63(6):502-7. [pmid: 12039527].
165 Sumnik Z, Kolouskova S, Cinek O, Kotalova R, Vavrinec J, Snajderova M. HLA-DQA1*05-DQB1*0201 positivity predisposes to coeliac disease in Czech diabetic children. Acta Paediatrica (Oslo, Norway - 1992). 2000;89(12):1426-30. [pmid: 11195230].
166 Liu J, Juo S, Holopainen P, Terwilliger J, Tong X, Grunn A, et al. Genomewide linkage analysis of celiac disease in Finnish families. American Journal of Human Genetics. 2002;70(1):51-9. [pmid: 11715113]. [pmcid: 384903].
167 Polvi A, Eland C, Koskimies S, Maki M, Partanen J. HLA DQ and DP in Finnish families with celiac disease. Eur J Immunogenet. 1996;23(3):221-34. [pmid: 8803535].
168 Larizza D, Calcaterra V, Luinetti O, Villani L, De Silvestri A, Autelli M, et al. Evidence for immunogenetic predisposition in children with celiac disease and autoimmune thyroid disease. Int J Med Biol Environ. 2001;29(2):143-8.
169 Book L, Zone J J, Neuhausen S L. Prevalence of celiac disease among relatives of sib pairs with celiac disease in U.S. families. American Journal of Gastroenterology. 2003;98(2):377-81. [pmid: 12591058].
170 Failla P, Ruberto C, Pagano M C, Lombardo M, Bottaro G, Perichon B, et al. Celiac disease in Down Syndrome with HLA serological and molecular studies. J Pediatr Gastroenterol Nutr. 1996;23(3):303-6. [pmid: 8890082].
171 Maki M, Mustalahti K, Kokkonen J, Kulmala P, Haapalahti M, Karttunen T, et al. Prevalence of Celiac disease among children in Finland. New England Journal of Medicine. 2003;348(25):2517-24. [pmid: 12815137].
172 Mustalahti K, Sulkanen S, Holopainen P, Laurila K, Collin P, Partanen J, et al. Coeliac disease among healthy members of multiple case coeliac disease families. Scandinavian Journal of Gastroenterology. 2002;37(2):161-5. [pmid: 11843051].
173 Zubillaga P, Vidales M C, Zubillaga I, Ormaechea V, Garcia-Urkia N, Vitoria J C. HLA-DQA1 and HLA-DQB1 genetic markers and clinical presentation in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 2002;34(5):548-54. [pmid: 12050583].
174 Bouguerra F, Babron M C, Eliaou J F, Debbabi A, Clot J, Khaldi F, et al. Synergistic effect of two HLA heterodimers in the susceptibility to celiac disease in Tunisia. Genetic Epidemiology. 1997;14(4):413-22. [pmid: 9271713].
175 Popat S, Hearle N, Wixey J, Hogberg L, Bevan S, Lim W, et al. Analysis of the CTLA4 gene in Swedish coeliac disease patients. Scand J Gastroenterol. 2002;37(1):28-31. [pmid: 11843030].
176 Karell K, Louka A S, Moodie S J, Ascher H, Clot F, Greco L, et al. HLA types in celiac disease patients not carrying the DQA1 *05-DQB1 *02 (DQ2) heterodimer: Results from the European genetics cluster on celiac disease. Hum Immunol. 2003;64(4):469-77. [pmid: 12651074].
177 Lewis C, Book L, Black J, Sawitzke A, Cannon-Albright L, Zone J, et al. Celiac disease and human leukocyte antigen genotype: accuracy of diagnosis in self-diagnosed individuals, dosage effect, and sibling risk. J Pediatr Gastroenterol Nutr. 2000;31(1):22-7. [pmid: 10896066].
178 Howard F M, Carter C O, Candy D C, Harries J T. A family study of protracted diarrhoea in infancy. Journal of Medical Genetics. 1981;18(2):81-6. [pmid: 7241538].
179 Volta U, Molinaro N, De Franceschi L, Bianchi F B. Human umbilical cord as substrate for IgA antiendomysial antibodies allows large scale screening for celiac sprue. J Clin Gastroenterol. 1996;23(1):18-20. [pmid: 8835893].
180 Trevisiol C, Ventura A, Baldas V, Tommasini A, Santon D, Martelossi S, et al. A reliable screening procedure for coeliac disease in clinical practice. Scand J Gastroenterol. 2002;37(6):679-84. [pmid: 12126246].
181 Bonamico M, Mariani P, Mazzilli M C, Triglione P, Lionetti P, Ferrante P, et al. Frequency and clinical pattern of celiac disease among siblings of celiac children. J Pediatr Gastroenterol Nutr. 1996;23(2):159-63. [pmid: 8856583].
182 Catassi C, Ratsch I M, Fabiani E, Ricci S, Bordicchia F, Pierdomenico R, et al. High prevalence of undiagnosed coeliac disease in 5280 Italian students screened by antigliadin antibodies. Acta Paediatr. 1995;84(6):672-6. [pmid: 7670254].
183 Catassi C, Ratsch I M, Fabiani E, Rossini M, Bordicchia F, Candela F, et al. Coeliac disease in the year 2000: exploring the iceberg. Lancet. 1994;343(8891):200-3. [pmid: 7904667].
184 Grodzinsky E, Hed J, Lieden G, Sjogren F, Strom M. Presence of IgA and IgG antigliadin antibodies in healthy adults as measured by micro-ELISA. Effect of various cutoff levels on specificity and sensitivity when diagnosing coeliac disease. Int Arch Allergy Appl Immunol. 1990;92(2):119-23. [pmid: 2242925].
185 Grodzinsky E, Franzen L, Hed J, Strom M. High prevalence of celiac disease in healthy adults revealed by antigliadin antibodies. Ann Allergy. 1992;69(1):66-70. [pmid: 1626762].
186 Lagerqvist C, Ivarsson A, Juto P, Persson L A, Hernell O. Screening for adult coeliac disease - which serological marker(s) to use?. J Intern Med. 2001;250(3):241-8. [pmid: 11555129].
187 Weile B, Grodzinsky E, Skogh T, Jordal R, Cavell B, Krasilnikoff P A. Screening Danish blood donors for antigliadin and antiendomysium antibodies. Acta Paediatr. 1996;412(Suppl):46.
188 McMillan S A, Watson R P, McCrum E E, Evans A E. Factors associated with serum antibodies to reticulin, endomysium, and gliadin in an adult population. Gut. 1996;39(1):43-7. [pmid: 8881807]. [pmcid: 1383229].
189 Stenhammar L, Brandt A, Wagermark J. A family study of coeliac disease. Acta Paediatr Scand. 1982;71(4):625-8. [pmid: 7136679].
190 Maki M, Holm K, Lipsanen V, Hallstrom O, Viander M, Collin P, et al. Serological markers and HLA genes among healthy first-degree relatives of patients with coeliac disease. Lancet. 1991;338(8779):1350-3. [pmid: 1682735].
191 Sjoberg K, Wassmuth R, Reichstetter S, Eriksson K F, Ericsson U B, Eriksson S. Gliadin antibodies in adult insulin-dependent diabetes--autoimmune and immunogenetic correlates. Autoimmunity. 2000;32(4):217-28. [pmid: 11191281].
192 Carlsson A K, Axelsson I E, Borulf S K, Bredberg A C, Lindberg B A, Sjoberg K G, et al. Prevalence of IgA-antiendomysium and IgA-antigliadin autoantibodies at diagnosis of insulin-dependent diabetes mellitus in Swedish children and adolescents. Pediatrics. 1999;103(6 Pt 1):1248-52. [pmid: 10353937].
193 Ivarsson A, Persson L A, Nystrom L, Ascher H, Cavell B, Danielsson L, et al. Epidemic of coeliac disease in Swedish children. Acta Paediatr. 2000;89(2):165-71. [pmid: 10709885].
194 Maki M, Holm K. Incidence and prevalence of coeliac disease in Tampere. Coeliac disease is not disappearing. Acta Paediatrica Scandinavica. 1990;79(10):980-2. [pmid: 2264477].
195 Ivarsson A, Persson L A, Nystrom L, Hernell O. The Swedish coeliac disease epidemic with a prevailing twofold higher risk in girls compared to boys may reflect gender specific risk factors. Eur J Epidemiol. 2003;18(7):677-84. [pmid: 12952142].
196 Weile B, Krasilnikoff P A. Extremely low incidence rates of celiac disease in the Danish population of children. J Clin Epidemiol. 1993;46(7):661-4. [pmid: 8326351].
197 Bode S, Gudmand-Hoyer E. Incidence and prevalence of adult coeliac disease within a defined geographic area in Denmark. Scand J Gastroenterol. 1996;31(7):694-9. [pmid: 8819220].
198 Maki M, Kallonen K, Lahdeaho M L, Visakorpi J K. Changing pattern of childhood coeliac disease in Finland. Acta Paediatrica Scandinavica. 1988;77(3):408-12. [pmid: 3389134].
199 Collin P, Reunala T, Rasmussen M, Kyronpalo S, Pehkonen E, Laippala P, et al. High incidence and prevalence of adult coeliac disease. Augmented diagnostic approach. Scand J Gastroenterol. 1997;32(11):1129-33. [pmid: 9399394].
200 Jansen Th T L A, Mulder C J J, Karssen P H Z, Wagenaar C G J. Epidemiological survey of the Dutch Coeliac Disease Society: An update 1992. Eur J Gastroenterol Hepatol. 1993;5(2):73-8.
201 Hawkes N D, Swift G L, Smith P M, Jenkins H R. Incidence and presentation of coeliac disease in South Glamorgan. Eur J Gastroenterol Hepatol. 2000;12(3):345-9. [pmid: 10750656].
202 Corrao G, Usai P, Galatola G, Ansaldi N, Meini A, Pelli M A, et al. Estimating the incidence of coeliac disease with capture-recapture methods within four geographic areas in Italy. J Epidemiol Community Health. 1996;50(3):299-305. [pmid: 8935462].
203 Magazzu G, Bottaro G, Cataldo F, Iacono G, Di Donato F, Patane R, et al. Increasing incidence of childhood celiac disease in Sicily: results of a multicenter study. Acta Paediatr. 1994;83(10):1065-9. [pmid: 7841706].
204 Lopez-Rodriguez M J, Canal Macias M L, Lavado Garcia J M, Sanchez B M, Robledo A P, Pedrera Zamorano J D. Epidemiological changes in diagnosed coeliac disease in a population of Spanish children. Acta Paediatr. 2003;92(2):165-9. [pmid: 12710641].
205 Talley N J, Valdovinos M, Petterson T M, Carpenter H A, Melton L J. Epidemiology of celiac sprue: a community-based study. Am J Gastroenterol. 1994;89(6):843-6. [pmid: 7864924].
206 Fasano A, Berti I, Gerarduzzi T, Not T, Colletti R B, Drago S, et al. Prevalence of celiac disease in at-risk and not-at-risk groups in the United States: a large multicenter study. Arch Intern Med. 2003;163(3):286-92. [pmid: 12578508].
207 Green P H, Shane E, Rotterdam H, Forde K A, Grossbard L. Significance of unsuspected celiac disease detected at endoscopy. Gastroenterol Int. 2000;51(1):60-5.
208 Not T, Horvath K, Hill I D, Partanen J, Hammed A, Magazzu G, et al. Celiac disease risk in the USA: high prevalence of antiendomysium antibodies in healthy blood donors. Scand J Gastroenterol. 1998;33(5):494-8. [pmid: 9648988].
209 Carlsson A K, Axelsson I E, Borulf S K, Bredberg A C, Ivarsson S A. Serological screening for celiac disease in healthy 2.5-year-old children in Sweden. Pediatrics. 2001;107(1):42-5. [pmid: 11134432].
210 Collin P, Rasmussen M, Kyronpalo S, Laippala P, Kaukinen K. The hunt for coeliac disease in primary care. Q J Med. 2002;95(2):75-7.
211 Grodzinsky E. Screening for coeliac disease in apparently healthy blood donors. Acta Paediatr. 1996;412(Suppl):36-8.
212 Hovdenak N, Hovlid E, Aksnes L, Fluge G, Erichsen M M, Eide J. High prevalence of asymptomatic coeliac disease in Norway: a study of blood donors. Eur J Gastroenterol Hepatol. 1999;11(2):185-7. [pmid: 10102231].
213 Ivarsson A, Persson L A, Juto P, Peltonen M, Suhr O, Hernell O. High prevalence of undiagnosed coeliac disease in adults: a Swedish population-based study. J Intern Med. 1999;245(1):63-8. [pmid: 10095818].
214 Kolho K L, Farkkila M A, Savilahti E. Undiagnosed coeliac disease is common in Finnish adults. Scand J Gastroenterol. 1998;33(12):1280-3. [pmid: 9930391].
215 Maki M, Mustalahti K, Kokkonen J, Kulmala P, Haapalahti M, Karttunen T, et al. Prevalence of Celiac disease among children in Finland. New Engl J Med. 2003;348(25):2517-24. [pmid: 12815137].
216 Sjoberg K, Alm R, Ivarsson S A, Lindstrom C, Eriksson S. Prevalence and clinical significance of gliadin antibodies in healthy children and adults. Scand J Gastroenterol. 1994;29(3):248-54. [pmid: 8209185].
217 Sjoberg K, Eriksson S. Regional differences in coeliac disease prevalence in Scandinavia?. Scand J Gastroenterol. 1999;34(1):41-5. [pmid: 10048731].
218 Weile I, Grodzinsky E, Skogh T, Jordal R, Cavell B, Krasilnikoff P A. High prevalence rates of adult silent coeliac disease, as seen in Sweden, must be expected in Denmark. APMIS. 2001;109(11):745-50. [pmid: 11900053].
219 Borch K, Grodzinsky E, Petersson F, Jonsson K-A, Mardh S, Valdimarsson T. Prevalence of coeliac disease and relations to Helicobacter pylori infection and duodenitis in a Swedish adult population sample: A histomorphological and serological survey. Inflammopharmacology. 2000;8(4):341-50.
220 Catassi C, Fabiani E, Ratsch I M, Coppa G V, Giorgi P L, Pierdomenico R, et al. The coeliac iceberg in Italy. A multicentre antigliadin antibodies screening for coeliac disease in school-age subjects. Acta Paediatr. 1996;412(Suppl):29-35.
221 Catassi C, Fanciulli G, D'Appello A R, El Asmar R, Rondina C, Fabiani E, et al. Antiendomysium versus antigliadin antibodies in screening the general population for coeliac disease. Scand J Gastroenterol. 2000;35(7):732-6. [pmid: 10972177].
222 Corazza G R, Andreani M L, Biagi F, Corrao G, Pretolani S, Giulianelli G, et al. The smaller size of the ‘coeliac iceberg’ in adults. Scand J Gastroenterol. 1997;32(9):917-9. [pmid: 9299671].
223 Mazzetti dP, Giorgetti G M, Gregori M, De Simone M, Leonardi C, Barletta P A, et al. Subclinical coeliac disease. Ital J Gastroenterol. 1992;24(6):352-4. [pmid: 1515663].
224 Pittschieler K, Ladinser B. Coeliac disease: screened by a new strategy. Acta Paediatr. 1996;412(Suppl):42-5.
225 Trevisiol C, Not T, Berti I, Buratti E, Citta A, Neri E, et al. Screening for coeliac disease in healthy blood donors at two immuno-transfusion centres in north-east Italy. Ital J Gastroenterol Hepatol. 1999;31(7):584-6. [pmid: 10604097].
226 Johnston S D, Watson R G, McMillan S A, Sloan J, Love A H. Coeliac disease detected by screening is not silent--simply unrecognized. Q J Med. 1998;91(12):853-60.
227 Sanders D S, Patel D, Stephenson T J, Ward A M, McCloskey E V, Hadjivassiliou M, et al. A primary care cross-sectional study of undiagnosed adult coeliac disease. Eur J Gastroenterol Hepatol. 2003;15(4):407-13. [pmid: 12655262].
228 West J, Logan R F A, Hill P G, Lloyd A, Lewis S, Hubbard R, et al. Seroprevalence, correlates, and characteristics of undetected coeliac disease in England. Gut. 2003;52(7):960-5. [pmid: 12801951]. [pmcid: 1773707].
229 Dickey W, McMillan S A, Bharucha C, Porter K G. Antigliadin antibodies in blood donors in Northern Ireland. Eur J Gastroenterol Hepatol. 1992;4(9):739-41.
230 Riestra S, Fernandez E, Rodrigo L, Garcia S, Ocio G. Prevalence of Coeliac disease in the general population of northern Spain. Strategies of serologic screening. Scand J Gastroenterol. 2000;35(4):398-402. [pmid: 10831263].
231 Rostami K, Mulder C J, Werre J M, van Beukelen F R, Kerchhaert J, Crusius J B, et al. High prevalence of celiac disease in apparently healthy blood donors suggests a high prevalence of undiagnosed celiac disease in the Dutch population. Scand J Gastroenterol. 1999;34(3):276-9. [pmid: 10232872].
232 Csizmadia C G D S, Mearin M L, Von Blomberg B M E, Brand R, Verloove-Vanhorick S P. An iceberg of childhood coeliac disease in the Netherlands. Lancet. 1999;353(9155):813-4. [pmid: 10459972].
233 Rutz R, Ritzler E, Fierz W, Herzog D. Prevalence of asymptomatic celiac disease in adolescents of eastern Switzerland. Swiss Med Wkly. 2002;132(34):43-7. [pmid: 11953905].
234 Jaeger C, Hatziagelaki E, Petzoldt R, Bretzel R G. Comparative analysis of organ-specific autoantibodies and celiac disease--associated antibodies in type 1 diabetic patients, their first-degree relatives, and healthy control subjects. Diabetes Care. 2001;24(1):27-32. [pmid: 11194235].
235 Book L, Zone J J, Neuhausen S L. Prevalence of celiac disease among relatives of sib pairs with celiac disease in U.S. families. Am J Gastroenterol. 2003;98(2):377-81. [pmid: 12591058].
236 Corazza G, Valentini R A, Frisoni M, Volta U, Corrao G, Bianchi F B, et al. Gliadin immune reactivity is associated with overt and latent enteropathy in relatives of celiac patients. Gastroenterology. 1992;103(5):1517-22. [pmid: 1426870].
237 Farre C, Humbert P, Vilar P, Varea V, Aldeguer X, Carnicer J, et al. Serological markers and HLA-DQ2 haplotype among first-degree relatives of celiac patients. Catalonian Coeliac Disease Study Group. Dig Dis Sci. 1999;44(11):2344-9. [pmid: 10573385].
238 Hill I, Fasano A, Schwartz R, Counts D, Glock M, Horvath K. The prevalence of celiac disease in at-risk groups of children in the United States. J Pediatr. 2000;136(1):86-90. [pmid: 10636980].
239 Korponay-Szabo I, Kovacs J, Lorincz M, Torok E, Goracz G. Families with multiple cases of gluten-sensitive enteropathy. Z Gastroenterol. 1998;36(7):553-8. [pmid: 9738302].
240 Kotze L M, Utiyama S R, Nisihara R M, Zeni M P, de Sena M G, Amarante H M. Antiendomysium antibodies in Brazilian patients with celiac disease and their first-degree relatives. Arq Gastroenterol. 2001;38(2):94-103. [pmid: 11793949].
241 Mustalahti K, Sulkanen S, Holopainen P, Laurila K, Collin P, Partanen J, et al. Coeliac disease among healthy members of multiple case coeliac disease families. Scand J Gastroenterol. 2002;37(2):161-5. [pmid: 11843051].
242 Robinson D C, Watson A J, Wyatt E H, Marks J M, Roberts D F. Incidence of small-intestinal mucosal abnormalities and of clinical coeliac disease in the relatives of children with coeliac disease. Gut. 1971;12(10):789-93. [pmid: 5123275]. [pmcid: 1411884].
243 Rolles C J, Myint T O, Sin W K, Anderson M. Proceedings: Family study of coeliac disease. Gut. 1974;15(10):827. [pmid: 4434938].
244 Rostami K, Mulder C J, van Overbeek F M, Kerckhaert J, Meijer J W, von Blomberg M B, et al. Should relatives of coeliacs with mild clinical complaints undergo a small-bowel biopsy despite negative serology?. Eur J Gastroenterol Hepatol. 2000;12(1):51-5. [pmid: 10656210].
245 Stokes P L, Ferguson R, Holmes G K, Cooke W T. Familial aspects of coeliac disease. Quarterly Journal of Medicine. 1976;45(180):567-82. [pmid: 1005655].
246 Vitoria J C, Arrieta A, Astigarraga I, Garcia-Masdevall D, Rodriguez-Soriano J. Use of serological markers as a screening test in family members of patients with celiac disease. J Pediatr Gastroenterol Nutr. 1994;19(3):304-9. [pmid: 7815262].
247 Hogberg L, Falth-Magnusson K, Grodzinsky E, Stenhammar L. Familial prevalence of coeliac disease: A twenty-year follow-up study. Scand J Gastroenterol. 2003;38(1):61-5. [pmid: 12608466].
248 Pittschieler K, Gentili L, Niederhofer H. Onset of coeliac disease: A prospective longitudinal study. Acta Paediatr Int J Paediatr. 2003;92(10):1149-52.
249 Tursi A, Brandimarte G, Giorgetti G M, Inchingolo C D. Effectiveness of the sorbitol HSUB2 breath test in detecting histological damage among relatives of coeliacs. Scand J Gastroenterol. 2003;38(7):727-31. [pmid: 12889558].
250 Acerini C L, Ahmed M L, Ross K M, Sullivan P B, Bird G, Dunger D B. Coeliac disease in children and adolescents with IDDM: clinical characteristics and response to gluten-free diet. Diabet Med. 1998;15(1):38-44. [pmid: 9472862].
251 Aktay A N, Lee P C, Kumar V, Parton E, Wyatt D T, Werlin S L. The prevalence and clinical characteristics of celiac disease in juvenile diabetes in Wisconsin. J Pediatr Gastroenterol Nutr. 2001;33(4):462-5. [pmid: 11698764].
252 Arato A, Korner A, Veres G, Dezsofi A, Ujpal I, Madacsy L. Frequency of coeliac disease in Hungarian children with type 1 diabetes mellitus. Eur J Pediatr. 2002;162(1):1-5. [pmid: 12486500].
253 Bao F, Yu L, Babu S, Wang T, Hoffenberg E J, Rewers M, et al. One third of HLA DQ2 homozygous patients with type 1 diabetes express celiac disease-associated transglutaminase autoantibodies. J Autoimmun. 1999;13(1):143-8. [pmid: 10441179].
254 Barera G, Bianchi C, Calisti L, Cerutti F, Dammacco F, Frezza E, et al. Screening of diabetic children for coeliac disease with antigliadin antibodies and HLA typing. Arch Dis Child. 1991;66(4):491-4. [pmid: 2031607].
255 Barera G, Bonfanti R, Viscardi M, Bazzigaluppi E, Calori G, Meschi F, et al. Occurrence of celiac disease after onset of type 1 diabetes: a 6-year prospective longitudinal study. Pediatrics. 2002;109(5):833-8. [pmid: 11986443].
256 Calero P, Ribes-Koninckx C, Albiach V, Carles C, Ferrer J. IgA antigliadin antibodies as a screening method for nonovert celiac disease in children with insulin-dependent diabetes mellitus. J Pediatr Gastroenterol Nutr. 1996;23(1):29-33. [pmid: 8811520].
257 Cronin C C, Feighery A, Ferriss J B, Liddy C, Shanahan F, Feighery C. High prevalence of celiac disease among patients with insulin-dependent (type I) diabetes mellitus. Am J Gastroenterol. 1997;92(12):2210-2. [pmid: 9399754].
258 De Block C E, De L I, Vertommen J J, Rooman R P, Du C M V, Van Campenhout C M, et al. Beta-cell, thyroid, gastric, adrenal and coeliac autoimmunity and HLA-DQ types in type 1 diabetes. Clin Exp Immunol. 2001;126(2):236-41. [pmid: 11703366]. [pmcid: 1906197].
259 De V I, Ghirlanda G, Gasbarrini G. Prevalence of coeliac disease in type I diabetes: a multicentre study. Acta Paediatr. 1996;412(Suppl):56-7.
260 Fraser-Reynolds K A, Butzner J D, Stephure D K, Trussell R A, Scott R B. Use of immunoglobulin A-antiendomysial antibody to screen for celiac disease in North American children with type 1 diabetes. Diabetes Care. 1998;21(11):1985-9. [pmid: 9802755].
261 Gillett P M, Gillett H R, Israel D M, Metzger D L, Stewart L, Chanoine J P, et al. High prevalence of celiac disease in patients with type 1 diabetes detected by antibodies to endomysium and tissue transglutaminase. Can J Gastroenterol. 2001;15(5):297-301. [pmid: 11381296].
262 Hansen D, Bennedbaek F N, Hansen L K, Hoier-Madsen M, Hegedu L S, Jacobsen B B, et al. High prevalence of coeliac disease in Danish children with type I diabetes mellitus. Acta Paediatr. 2001;90(11):1238-43. [pmid: 11808892].
263 Kaukinen K, Collin P, Mykkanen A H, Partanen J, Maki M, Salmi J. Celiac disease and autoimmune endocrinologic disorders. Dig Dis Sci. 1999;44(7):1428-33. [pmid: 10489930].
264 Kordonouri O, Dieterich W, Schuppan D, Webert G, Muller C, Sarioglu N, et al. Autoantibodies to tissue transglutaminase are sensitive serological parameters for detecting silent coeliac disease in patients with Type 1 diabetes mellitus. Diabet Med. 2000;17(6):441-4. [pmid: 10975212].
265 Lampasona V, Bonfanti R, Bazzigaluppi E, Venerando A, Chiumello G, Bosi E, et al. Antibodies to tissue transglutaminase C in type I diabetes. Diabetologia. 1999;42(10):1195-8. [pmid: 10525659].
266 Li Voon Chong J S W, Leong K S, Wallymahmed M, Sturgess R, MacFarlane I A. Is coeliac disease more prevalent in young adults with coexisting Type 1 diabetes mellitus and autoimmune thyroid disease compared with those with Type 1 diabetes mellitus alone?. Diabet Med. 2002;19(4):334-7. [pmid: 11943007].
267 Lorini R, Scotta M S, Cortona L, Avanzini M A, Vitali L, De Giacomo C, et al. Celiac disease and type I (insulin-dependent) diabetes mellitus in childhood: follow-up study. J Diabetes Complications. 1996;10(3):154-9. [pmid: 8807465].
268 Not T, Tommasini A, Tonini G, Buratti E, Pocecco M, Tortul C, et al. Undiagnosed coeliac disease and risk of autoimmune disorders in subjects with Type I diabetes mellitus. Diabetologia. 2001;44(2):151-5. [pmid: 11270670].
269 Page S R, Lloyd C A, Hill P G, Peacock I, Holmes G K. The prevalence of coeliac disease in adult diabetes mellitus. Q J Med. 1994;87(10):631-7.
270 Rensch M J, Merenich J A, Lieberman M, Long B D, Davis D R, McNally P R. Gluten-sensitive enteropathy in patients with insulin-dependent diabetes mellitus. Ann Intern Med. 1996;124(6):564-7. [pmid: 8597319].
271 Roldan M B, Barrio R, Roy G, Parra C, Alonso M, Yturriaga R, et al. Diagnostic value of serological markers for celiac disease in diabetic children and adolescents. J Pediatr Endocrinol Metab. 1998;11(6):751-6. [pmid: 9829231].
272 Rossi T M, Albini C H, Kumar V. Incidence of celiac disease identified by the presence of serum endomysial antibodies in children with chronic diarrhea, short stature, or insulin-dependent diabetes mellitus. J Pediatr. 1993;123(2):262-4. [pmid: 8345423].
273 Sategna-Guidetti C, Grosso S, Pulitano R, Benaduce E, Dani F, Carta Q. Celiac disease and insulin-dependent diabetes mellitus. Screening in an adult population. Dig Dis Sci. 1994;39(8):1633-7. [pmid: 8050311].
274 Saukkonen T, Savilahti E, Reijonen H, Ilonen J, Tuomilehto-Wolf E, Akerblom H K. Coeliac disease: frequent occurrence after clinical onset of insulin-dependent diabetes mellitus. Childhood Diabetes in Finland Study Group. Diabet Med. 1996;13(5):464-70. [pmid: 8737029].
275 Schober E, Bittmann B, Granditsch G, Huber W D, Huppe A, Jager A, et al. Screening by anti-endomysium antibody for celiac disease in diabetic children and adolescents in Austria. J Pediatr Gastroenterol Nutr. 2000;30(4):391-6. [pmid: 10776949].
276 Sigurs N, Johansson C, Elfstrand P O, Viander M, Lanner A. Prevalence of coeliac disease in diabetic children and adolescents in Sweden. Acta Paediatr. 1993;82(9):748-51. [pmid: 8241671].
277 Sjoberg K, Eriksson K F, Bredberg A, Wassmuth R, Eriksson S. Screening for coeliac disease in adult insulin-dependent diabetes mellitus. J Intern Med. 1998;243(2):133-40. [pmid: 9566642].
278 Spiekerkoetter U, Seissler J, Wendel U. General screening for celiac disease is advisable in children with type 1 diabetes. Horm Metab Res. 2002;34(4):192-5. [pmid: 11987028].
279 Talal A H, Murray J A, Goeken J A, Sivitz W I. Celiac disease in an adult population with insulin-dependent diabetes mellitus: use of endomysial antibody testing. Am J Gastroenterol. 1997;92(8):1280-4. [pmid: 9260789].
280 Valerio G, Maiuri L, Troncone R, Buono P, Lombardi F, Palmieri R, et al. Severe clinical onset of diabetes and increased prevalence of other autoimmune diseases in children with coeliac disease diagnosed before diabetes mellitus. Diabetologia. 2002;45(12):1719-22. [pmid: 12488963].
281 Vitoria J C, Castano L, Rica I, Bilbao J R, Arrieta A, Garcia-Masdevall M D. Association of insulin-dependent diabetes mellitus and celiac disease: a study based on serologic markers. J Pediatr Gastroenterol Nutr. 1998;27(1):47-52. [pmid: 9669725].
282 Agardh D, Nilsson A, Tuomi T, Lindberg B, Carlsson A K, Lernmark A, et al. Prediction of silent celiac disease at diagnosis of childhood type 1 diabetes by tissue transglutaminase autoantibodies and HLA. Pediatr Diabetes. 2001;2(2):58-65. [pmid: 15016199].
283 Ackerman Z, Eliakim R, Stalnikowicz R, Rachmilewitz D. Role of small bowel biopsy in the endoscopic evaluation of adults with iron deficiency anemia. Am J Gastroenterol. 1996;91(10):2099-102. [pmid: 8855729].
284 Annibale B, Capurso G, Chistolini A, D'Ambra G, DiGiulio E, Monarca B, et al. Gastrointestinal causes of refractory iron deficiency anemia in patients without gastrointestinal symptoms. Am J Med. 2001;111(6):439-45. [pmid: 11690568].
285 Corazza G R, Valentini R A, Andreani M L, D'Anchino M, Leva M T, Ginaldi L, et al. Subclinical coeliac disease is a frequent cause of iron-deficiency anaemia. Scand J Gastroenterol. 1995;30(2):153-6. [pmid: 7732338].
286 Dickey W, Kenny B D, McMillan S A, Porter K G, McConnell J B. Gastric as well as duodenal biopsies may be useful in the investigation of iron deficiency anaemia. Scand J Gastroenterol. 1997;32(5):469-72. [pmid: 9175209].
287 Howard M R, Turnbull A J, Morley P, Hollier P, Webb R, Clarke A. A prospective study of the prevalence of undiagnosed coeliac disease in laboratory defined iron and folate deficiency. J Clinl Path. 2002;55(10):754-7.
288 Kepczyk T, Kadakia S C. Prospective evaluation of gastrointestinal tract in patients with iron-deficiency anemia. Dig Dis Sci. 1995;40(6):1283-9. [pmid: 7781448].
289 McIntyre A S, Long R G. Prospective survey of investigations in outpatients referred with iron deficiency anaemia. Gut. 1993;34(8):1102-7. [pmid: 8174963]. [pmcid: 1374363].
290 Oxentenko A S, Grisolano S W, Murray J A, Burgart L J, Dierkhising R A, Alexander J A. The insensitivity of endoscopic markers in celiac disease. Am J Gastroenterol. 2002;97(4):933-8. [pmid: 12003429].
291 Ransford Rupert A J, Hayes M, Palmer M, Hall M J. A controlled, prospective screening study of celiac disease presenting as iron deficiency anemia. J Clin Gastroenterol. 2002;35(3):228-33. [pmid: 12192198].
292 Unsworth D J, Lock R J, Harvey R F. Improving the diagnosis of coeliac disease in anaemic women. Br J Haematol. 2000;111(3):898-901. [pmid: 11122153].
293 Annibale B, Lahner E, Chistolini A, Gallucci C, Di Giulio E, Capurso G, et al. Endoscopic evaluation of the upper gastrointestinal tract is worthwhile in premenopausal women with iron-deficiency anaemia irrespective of menstrual flow. Scand J Gastroenterol. 2003;38(3):239-45. [pmid: 12737437].
294 Van Mook W N K A, Bourass-Bremer I H D N, Bos L P, Verhoeven H M J M, Engels L G J B. The outcome of esophagogastroduodenoscopy (EGD) in asymptomatic outpatients with iron deficiency anemia after a negative colonoscopy. Eur J Intern Med. 2001;12(2):122-6. [pmid: 11297915].
295 Gonzalez D, Sugai E, Gomez J C, Oliveri M B, Gomez A C, Vega E, et al. Is it necessary to screen for celiac disease in postmenopausal osteoporotic women?. Calcif Tissue Int. 2002;71(2):141-4. [pmid: 12200648].
296 Lindh E, Ljunghall S, Larsson K, Lavo B. Screening for antibodies against gliadin in patients with osteoporosis. J Intern Med. 1992;231(4):403-6. [pmid: 1588266].
297 Mather K J, Meddings J B, Beck P L, Scott R B, Hanley D A. Prevalence of IgA-antiendomysial antibody in asymptomatic low bone mineral density. Am J Gastroenterol. 2001;96(1):120-5. [pmid: 11197240].
298 Nuti R, Martini G, Valenti R, Giovani S, Salvadori S, Avanzati A. Prevalence of undiagnosed coeliac syndrome in osteoporotic women. J Intern Med. 2001;250(4):361-6. [pmid: 11576323].
299 Hin H, Bird G, Fisher P, Mahy N, Jewell D. Coeliac disease in primary care: case finding study. BMJ. 1999;318(7177):164-7. [pmid: 9888912]. [pmcid: 27697].
300 Bardella M T, Molteni N, Cesana B, Baldassarri A R, Binanchi P A. IgA antigliadin antibodies, cellobiose/mannitol sugar test, and carotenemia in the diagnosis of and screening for celiac disease. Am J Gastroenterol. 1991;86(3):309-11. [pmid: 1900142].
301 Bardella M T, Trovato C, Cesana B M, Pagliari C, Gebbia C, Peracchi M. Serological markers for coeliac disease: is it time to change?. Dig Liver Dis. 2001;33(5):426-31. [pmid: 11529655].
302 Bode S, Weile B, Krasilnikoff P A, Gudmand-Hoyer E. The diagnostic value of the gliadin antibody test in celiac disease in children: a prospective study. J Pediatr Gastroenterol Nutr. 1993;17(3):260-4. [pmid: 8271124].
303 Carroccio A, Vitale G, Di Prima L, Chifari N, Napoli S, La Russa C, et al. Comparison of anti-transglutaminase ELISAs and an anti-endomysial antibody assay in the diagnosis of celiac disease: a prospective study. Clin Chem. 2002;48(9):1546-50. [pmid: 12194932].
304 Chan A W, Butzner J D, McKenna R, Fritzler M J. Tissue transglutaminase enzyme-linked immunosorbent assay as a screening test for celiac disease in pediatric patients. Pediatrics. 2001;107(1):E8. [pmid: 11134472].
305 Chartrand L J, Agulnik J, Vanounou T, Russo P A, Baehler P, Seidman E G. Effectiveness of antigliadin antibodies as a screening test for celiac disease in children. CMAJ. 1997;157(5):527-33. [pmid: 9294391]. [pmcid: 1227966].
306 Day A S, Cook H B, Whitehead M, Abbott G D. Anti-endomysial and anti-gliadin antibodies in screening for coeliac disease in children at greater risk of developing coeliac disease. N Z Med J. 2000;113(1119):412-3. [pmid: 11127356].
307 Fitzpatrick K P, Sherman P M, Ipp M, Saunders N, Macarthur C. Screening for celiac disease in children with recurrent abdominal pain. J Pediatr Gastroenterol Nutr. 2001;33(3):250-2. [pmid: 11593117].
308 Thomas A G, Phillips A D, Walker-Smith J A. The value of proximal small intestinal biopsy in the differential diagnosis of chronic diarrhoea. Arch Dis Child. 1992;67(6):741-3. [pmid: 1626996].
309 Ventura A, Facchini S, Amantidu C, Andreotti M F, Andrighetto A, Baggiani A, et al. Searching for celiac disease in pediatric general practice. Clin Pediatr. 2001;40(10):575-7.
310 Ascher H, Krantz I, Kristiansson B. Increasing incidence of coeliac disease in Sweden. Arch Dis Child. 1991;66(5):608-11. [pmid: 2039251].
311 Cavell B, Stenhammar L, Ascher H, Danielsson L, Dannaeus A, Lindberg T, et al. Increasing incidence of childhood coeliac disease in Sweden. Results of a national study. Acta Paediatr. 1992;81(8):589-92. [pmid: 1392381].
312 Stenhammar L, Johansson C G. The incidence of coeliac disease in children in south-east Sweden. Acta Paediatrica Scandinavica. 1981;70(3):379-81. [pmid: 7246129].
313 Weile B, Cavell B, Nivenius K, Krasilnikoff P A. Striking differences in the incidence of childhood celiac disease between Denmark and Sweden: a plausible explanation. J Pediatr Gastroenterol Nutr. 1995;21(1):64-8. [pmid: 8576817].
314 Weile B, Krasilnikoff P A. Low incidence rates by birth of symptomatic coeliac disease in a Danish population of children. Acta Paediatr. 1992;81(5):394-8. [pmid: 1498504].
315 Stevens F M, Egan-Mitchell B, Cryan E, McCarthy C F, McNicholl B. Decreasing incidence of coeliac disease. Arch Dis Child. 1987;62(5):465-8. [pmid: 3606178].
316 Logan R F, Rifkind E A, Busuttil A, Gilmour H M, Ferguson A. Prevalence and “incidence” of celiac disease in Edinburgh and the Lothian region of Scotland. Gastroenterology. 1986;90(2):334-42. [pmid: 3484455].
317 Hoffenberg E J, Bao F, Eisenbarth G S, Uhlhorn C, Haas J E, Sokol R J, et al. Transglutaminase antibodies in children with a genetic risk for celiac disease. Journal of Pediatrics. 2000;137(3):356-60. [pmid: 10969260].
318 Corazza G R, Frisoni M, Treggiari E A, Valentini R A, Filipponi C, Volta U, et al. Subclinical celiac sprue. Increasing occurrence and clues to its diagnosis. J Clin Gastroenterol. 1993;16(1):16-21. [pmid: 8421137].
319 Sanders D S, Hurlstone D P, Stokes R O, Rashid F, Milford-Ward A, Hadjivassiliou M, et al. Changing face of adult coeliac disease: experience of a single university hospital in South Yorkshire. Postgraduate Medical Journal. 2002;78(915):31-3. [pmid: 11796869].
320 Sategna-Guidetti C, Grosso S. Changing pattern in adult coeliac disease: A 24-year survey. Eur J Gastroenterol Hepatol. 1994;6(1):15-9.
321 Holmes G K. Non-malignant complications of coeliac disease. Acta Paediatrica Supplement. 1996;412:68-75. [pmid: 8783765].
322 Suharjono. Intestinal biopsy and coeliac disease. Paediatrica Indonesiana. 1971;11(3):116-34. [pmid: 5154768].
323 Mannell A, van Heerden J A, Weiland L H, Ilstrup D M. Factors influencing survival after resection for ductal adenocarcinoma of the pancreas. Annals of Surgery. 1986;203(4):403-7. [pmid: 3008674]. [pmcid: 1251125].
324 Atherton D J. Diagnosis and management of skin disorders caused by food allergy. Annals of Allergy. 1984;53(6 Pt 2):623-8. [pmid: 6391291].
325 Di Stefano M, Jorizzo R A, Veneto G, Cecchetti L, Gasbarrini G, Corazza G R. Bone mass and metabolism in dermatitis herpetiformis. Dig Dis Sci. 1999;44(10):2139-43. [pmid: 10548369].
326 Ots M, Uibo O, Metskula K, Uibo R, Salupere V. IgA-antigliadin antibodies in patients with IgA nephropathy: the secondary phenomenon?. American Journal of Nephrology. 1999;19(4):453-8. [pmid: 10460933].
327 Collin P, Reunala T, Pukkala E, Laippala P, Keyrilainen O, Pasternack A. Coeliac disease--associated disorders and survival. Gut. 1994;35(9):1215-8. [pmid: 7959226]. [pmcid: 1375696].
328 Cooper B T, Holmes G K, Cooke W T. Lymphoma risk in coeliac disease of later life. Digestion. 1982;23(2):89-92. [pmid: 7095316].
329 Harris O D, Cooke W T, Thompson H, Waterhouse J A. Malignancy in adult coeliac disease and idiopathic steatorrhoea. Am J Med. 1967;42(6):899-912. [pmid: 5338480].
330 Holmes G K, Stokes P L, Sorahan T M, Prior P, Waterhouse J A, Cooke W T. Coeliac disease, gluten-free diet, and malignancy. Gut. 1976;17(8):612-9. [pmid: 789184]. [pmcid: 1411326].
331 Peters U, Askling J, Gridley G, Ekbom A, Linet M. Causes of death in patients with celiac disease in a population-based Swedish cohort. Archives of Internal Medicine. 2003;163(13):1566-72. [pmid: 12860579].
332 Cooper B T, Holmes G K T, Ferguson R. Celiac disease and malignancy. Medicine. 1980;59(4):249-61. [pmid: 7392945].
333 Holmes G K, Prior P, Lane M R, Pope D, Allan R N. Malignancy in coeliac disease--effect of a gluten free diet. Gut. 1989;30(3):333-8. [pmid: 2707633]. [pmcid: 1378455].
334 Sorensen H T, Fonager K. Risk estimation of disorders associated with coeliac disease. A 16-year Danish nationwide follow-up study based on hospital discharge data. Implications for screening. Int J Risk Saf Med. 1996;8(2):137-40.
335 Cottone M, Termini A, Oliva L, Magliocco A, Marrone C, Orlando A, et al. Mortality and causes of death in celiac disease in a Mediterranean area. Dig Dis Sci. 1999;44(12):2538-41. [pmid: 10630509].
336 Logan R F, Rifkind E A, Turner I D, Ferguson A. Mortality in celiac disease. Gastroenterology. 1989;97(2):265-71. [pmid: 2744350].
337 Askling J, Linet M, Gridley G, Halstensen T S, Ekstrom K, Ekbom A. Cancer incidence in a population-based cohort of individuals hospitalized with celiac disease or dermatitis herpetiformis. Gastroenterology. 2002;123(5):1428-35. [pmid: 12404215].
338 Collin P, Pukkala E, Reunala T. Malignancy and survival in dermatitis herpetiformis: a comparison with coeliac disease. Gut. 1996;38(4):528-30. [pmid: 8707082]. [pmcid: 1383109].
339 Corrao G, Corazza G R, Bagnardi V, Brusco G, Ciacci C, Cottone M, et al. Mortality in patients with coeliac disease and their relatives: a cohort study. Lancet. 2001;358(9279):356-61. [pmid: 11502314].
340 Green P H R, Fleischauer A T, Bhagat G, Goyal R, Jabri B, Neugut A I. Risk of malignancy in patients with celiac disease. Am J Med. 2003;115(3):191-5. [pmid: 12935825].
341 Selby W S, Gallagher N D. Malignancy in a 19-year experience of adult celiac disease. Dig Dis Sci. 1979;24(9):684-8. [pmid: 487922].
342 Delco F, El Serag H B, Sonnenberg A. Celiac sprue among US military veterans: associated disorders and clinical manifestations. Dig Dis Sci. 1999;44(5):966-72. [pmid: 10235605].
343 Nielsen O H, Jacobsen O, Pedersen E R, Rasmussen S N, Petri M, Laulund S, et al. Non-tropical sprue. Malignant diseases and mortality rate. Scand J Gastroenterol. 1985;20(1):13-8. [pmid: 3992161].
344 Shainoff J R, Valenzuela R, Urbanic D A, DiBello P M, Lucas F V, Graor R. Fibrinogen A alpha and gamma-chain dimers as potential differential indicators of atherosclerotic and thrombotic vascular disease. Blood Coagulation & Fibrinolysis - an International Journal in Haemostasis and Thrombosis. 1990;1(45):499-503. [pmid: 1983461].
345 Ribes-Koninckx C, Alfonso P, Ortigosa L, Escobar H, Suarez L, Arranz E, et al. A beta-turn rich oats peptide as an antigen in an ELISA method for the screening of coeliac disease in a paediatric population. European Journal of Clinical Investigation. 2000;30(8):702-8. [pmid: 10964162].
346 Kemppainen T A, Kosma V M, Janatuinen E K, Julkunen R J, Pikkarainen P H, Uusitupa M I. Nutritional status of newly diagnosed celiac disease patients before and after the institution of a celiac disease diet--association with the grade of mucosal villous atrophy. Am J Clin Nutr. 1998;67(3):482-7. [pmid: 9497194].
347 Amin R, Murphy N, Edge J, Ahmed M L, Acerini C L, Dunger D B. A longitudinal study of the effects of a gluten-free diet on glycemic control and weight gain in subjects with type 1 diabetes and celiac disease. Diabetes Care. 2002;25(7):1117-22. [pmid: 12087007].
348 Bardella M T, Fredella C, Prampolini L, Molteni N, Giunta A M, Bianchi P A. Body composition and dietary intakes in adult celiac disease patients consuming a strict gluten-free diet. Am J Clin Nutr. 2000;72(4):937-9. [pmid: 11010934].
349 Barera G, Mora S, Brambilla P, Ricotti A, Menni L, Beccio S, et al. Body composition in children with celiac disease and the effects of a gluten-free diet: a prospective case-control study. Am J Clin Nutr. 2000;72(1):71-5. [pmid: 10871563].
350 Boersma B, Houwen R H J, Blum W F, van Doorn J, Wit J M. Catch-up growth and endocrine changes in childhood celiac disease. Endocrine changes during catch-up growth. Horm Res. 2002;58(Suppl 1):57-65. [pmid: 12373016].
351 Ciacci C, Cirillo M, Auriemma G, Di Dato G, Sabbatini F, Mazzacca G. Celiac disease and pregnancy outcome. Am J Gastroenterol. 1996;91(4):718-22. [pmid: 8677936].
352 Rea F, Polito C, Marotta A, Di Toro A, Iovene A, Collini R, et al. Restoration of body composition in celiac children after one year of gluten-free diet. J Pediatr Gastroenterol Nutr. 1996;23(4):408-12. [pmid: 8956176].
353 Sategna-Guidetti C, Grosso S B, Grosso S, Mengozzi G, Aimo G, Zaccaria T, et al. The effects of 1-year gluten withdrawal on bone mass, bone metabolism and nutritional status in newly-diagnosed adult coeliac disease patients. Aliment Pharmacol Ther. 2000;14(1):35-43. [pmid: 10632643].
354 Sategna-Guidetti C, Volta U, Ciacci C, Usai P, Carlino A, De Franceschi L, et al. Prevalence of thyroid disorders in untreated adult celiac disease patients and effect of gluten withdrawal: an Italian multicenter study. Am J Gastroenterol. 2001;96(3):751-7. [pmid: 11280546].
355 Valdimarsson T, Lofman O, Toss G, Strom M. Reversal of osteopenia with diet in adult coeliac disease. Gut. 1996;38(3):322-7. [pmid: 8675082]. [pmcid: 1383058].
356 Valdimarsson T, Toss G, Lofman O, Strom M. Three years' follow-up of bone density in adult coeliac disease: significance of secondary hyperparathyroidism. Scand J Gastroenterol. 2000;35(3):274-80. [pmid: 10766321].
357 Westman E, Ambler G R, Royle M, Peat J, Chan A. Children with coeliac disease and insulin dependent diabetes mellitus--growth, diabetes control and dietary intake. J Pediatr Endocrinol Metab. 1999;12(3):433-42. [pmid: 10821223].
358 Annibale B, Severi C, Chistolini A, Antonelli G, Lahner E, Marcheggiano A, et al. Efficacy of gluten-free diet alone on recovery from iron deficiency anemia in adult celiac patients. Am J Gastroenterol. 2001;96(1):132-7. [pmid: 11197242].
359 Arato A, Korner A, Veres G, Dezsofi A, Ujpal I, Madacsy L. Frequency of coeliac disease in Hungarian children with type 1 diabetes mellitus. Eur J Pediatr. 2002;162(1):1-5. [pmid: 12486500].
360 Atkinson K, Tokmakajian S, Watson W, Gregor J. Evaluation of the endomysial antibody for celiac disease: operating properties and associated cost implications in clinical practice. Can J Gastroenterol. 1997;11(8):673-7. [pmid: 9459047].
361 Bardella M T, Molteni N, Quatrini M, Velio P, Ranzi T, Bianchi P A. Clinical, biochemical and histological abnormalities in adult celiac patients on gluten-free diet. Gastroenterol Clin Biol. 1985;9(11):787-9. [pmid: 4085741].
362 Corrao G, Corazza G R, Bagnardi V, Brusco G, Ciacci C, Cottone M, et al. Mortality in patients with coeliac disease and their relatives: a cohort study. Lancet. 2001;358(9279):356-61. [pmid: 11502314].
363 Fabiani E, Catassi C, Villari A, Gismondi P, Pierdomenico R, Ratsch I M, et al. Dietary compliance in screening-detected coeliac disease adolescents. Acta Paediatr. 1996;412(Suppl):65-7.
364 Fabiani E, Taccari L M, Ratsch I M, Di Giuseppe S, Coppa G V, Catassi C. Compliance with gluten-free diet in adolescents with screening-detected celiac disease: a 5-year follow-up study. J Pediatr. 2000;136(6):841-3. [pmid: 10839888].
365 Greco L, Mayer M, Ciccarelli G, Troncone R, Auricchio S. Compliance to a gluten-free diet in adolescents, or “what do 300 coeliac adolescents eat every day?”. Ital J Gastroenterol Hepatol. 1997;29(4):305-10. [pmid: 9476181].
366 Harewood G C, Murray J A. Diagnostic approach to a patient with suspected celiac disease: a cost analysis. Dig Dis Sci. 2001;46(11):2510-4. [pmid: 11713962].
367 Holmes G K, Stokes P L, Sorahan T M, Prior P, Waterhouse J A, Cooke W T. Coeliac disease, gluten-free diet, and malignancy. Gut. 1976;17(8):612-9. [pmid: 789184]. [pmcid: 1411326].
368 Johnston S D, Watson R G, McMillan S A, Sloan J, Love A H. Coeliac disease detected by screening is not silent--simply unrecognized. Qjm. 1998;91(12):853-60. [pmid: 10024951].
369 Poddar U, Thapa B R, Nain C K, rasad A, ingh K. Celiac disease in India: are they true cases of celiac disease?. J Pediatr Gastroenterol Nutr. 2002;35(4):508-12. [pmid: 12394375].
370 Saukkonen T, Vaisanen S, Akerblom H K, Savilahti E. Coeliac disease in children and adolescents with type 1 diabetes: a study of growth, glycaemic control, and experiences of families. Acta Paediatr. 2002;91(3):297-302. [pmid: 12022302].
371 Smecuol E, Gonzalez D, Mautalen C, Siccardi A, Cataldi M, Niveloni S, et al. Longitudinal study on the effect of treatment on body composition and anthropometry of celiac disease patients. Am J Gastroenterol. 1997;92(4):639-43. [pmid: 9128314].
372 Bowron A, Moorghen M, Morgan J E, Osborne J R, Stansbie D, Stone J E. Cost-effective strategy for the serological investigation of coeliac disease. Ann Clin Biochem. 2000;37(4):467-70. [pmid: 10902862].
373 Thomason K, West J, Logan R F A, Coupland C, Holmes G K T. Fracture experience of patients with coeliac disease: a population based survey. Gut. 2003;52(4):518-22. [pmid: 12631662]. [pmcid: 1773600].
374 Addolorato G, Capristo E, Ghittoni G, Valeri C, Masciana R, Ancona C, et al. Anxiety but not depression decreases in coeliac patients after one-year gluten-free diet: a longitudinal study. Scand J Gastroenterol. 2001;36(5):502-6. [pmid: 11346203].
375 Bai J C, Gonzalez D, Mautalen C, Mazure R, Pedreira S, Vazquez H, et al. Long-term effect of gluten restriction on bone mineral density of patients with coeliac disease. Aliment Pharmacol Ther. 1997;11(1):157-64. [pmid: 9042988].
376 Kemppainen T, Kroger H, Janatuinen E, Arnala I, Lamberg-Allardt C, Karkkainen M, et al. Bone recovery after a gluten-free diet: a 5-year follow-up study. Bone. 1999;25(3):355-60. [pmid: 10495140].
377 Mora S, Barera G, Beccio S, Menni L, Proverbio M C, Bianchi C, et al. A prospective, longitudinal study of the long-term effect of treatment on bone density in children with celiac disease. J Pediatr. 2001;139(4):516-21. [pmid: 11598597].
378 Mustalahti K, Collin P, Sievanen H, Salmi J, Maki M. Osteopenia in patients with clinically silent coeliac disease warrants screening. Lancet. 1999;354(9180):744-5. [pmid: 10475193].
379 Zaccari G, Mazzetti dP, Paone F M, Guidiceandrea P. A proposal for coeliac disease screening of all infants at the age of fifteen months. Gastroenterol Int. 1996;9(1):11-5.
380 Bowron A, Moorghen M, Morgan J E, Osborne J R, Stansbie D, Stone J E. Cost-effective strategy for the serological investigation of coeliac disease. Ann Clin Biochem. 2000;37(4):467-70. [pmid: 10902862].
381 Bernstein C N, Leslie W D, Leboff M S. AGA technical review on osteoporosis in gastrointestinal diseases. Gastroenterology. 2003;124(3):795-841. [pmid: 12949738].
382 Gomez J C, Selvaggio G, Pizarro B, Viola M J, La Motta G, Smecuol E, et al. Value of a screening algorithm for celiac disease using tissue transglutaminase antibodies as first level in a population-based study. American Journal of Gastroenterology. 2002;97(11):2785-90. [pmid: 12425549].
383 Kemppainen T, Kroger H, Janatuinen E, Arnala I, Kosma V M, Pikkarainen P, et al. Osteoporosis in adult patients with celiac disease. Bone. 1999;24(3):249-55. [pmid: 10071918].
384 Mora S, Barera G, Beccio S, Proverbio M C, Weber G, Bianchi C, et al. Bone density and bone metabolism are normal after long-term gluten-free diet in young celiac patients. Am J Gastroenterol. 1999;94(2):398-403. [pmid: 10022636].
385 West J, Logan Richard F A, Card T R, Smith C, Hubbard R. Fracture risk in people with celiac disease: a population-based cohort study. Gastroenterology. 2003;125(2):429-36. [pmid: 12891545].
386 Ciacci C, Maurelli L, Klain M, Savino G, Salvatore M, Mazzacca G, et al. Effects of dietary treatment on bone mineral density in adults with celiac disease: factors predicting response. Am J Gastroenterol. 1997;92(6):992-6. [pmid: 9177517].
387 McFarlane X A, Bhalla A K, Robertson D A. Effect of a gluten free diet on osteopenia in adults with newly diagnosed coeliac disease. Gut. 1996;39(2):180-4. [pmid: 8991855]. [pmcid: 1383295].
388 Vestergaard P, Mosekilde L. Fracture risk in patients with celiac Disease, Crohn's disease, and ulcerative colitis: a nationwide follow-up study of 16,416 patients in Denmark. Am J Epidemiol 2002;156(1):1–10. Available: PM:12076883.
389 Vasquez H, Mazure R, Gonzalez D, Flores D, Pedreira S, Niveloni S, et al. Risk of fractures in celiac disease patients: a cross-sectional, case-control study. Am J Gastroenterol 2000;95(1):183–9. Available: PM:10638580.
390 Fickling WE, McFarlane XA, Bhalla AK, Robertson DA. The clinical impact of metabolic bone disease in coeliac disease. Postgrad Med J 2001;77(903):33–6. Available: PM:11123392.
391 Bianchi ML, Bardella MT. Bone and celiac disease. Calcif Tissue Int 2002;71(6):465–71. Available: PM:12232681.
392 Moreno ML, Vazquez H, Mazure R, Smecuol E, Niveloni S, Pedreira S, et al. Stratification of bone fracture risk in patients with celiac disease. Clin Gastroenterol Hepatol 2004;2(2):127–34. Available: PM:15017617.
393 Norgard B, Fonager K, Sorensen H T, Olsen J. Birth outcomes of women with celiac disease: A nationwide historical cohort study. Am J Gastroenterol. 1999;94(9):2435-40. [pmid: 10484005].
394 Thomason K, West J, Logan R F A, Coupland C, Holmes G K T. Fracture experience of patients with coeliac disease: a population based survey. Gut. 2003;52(4):518-22. [pmid: 12631662]. [pmcid: 1773600].
395 Cook H B, Burt M J, Collett J A, Whitehead M R, Frampton C M, Chapman B A. Adult coeliac disease: prevalence and clinical significance. J Gastroenterol Hepatol. 2000;15(9):1032-6. [pmid: 11059933].
396 Bartholomeusz R C, Labrooy J T, Davidson G P, Hetzel P, Johnson R B, Shearman D J. Polymeric IgA antibody to gliadin in the serum of patients with coeliac disease. J Gastroenterol Hepatol. 1990;5(6):675-81. [pmid: 2129839].
397 Fotoulaki M, Nousia-Arvanitakis S, Augoustidou-Savvopoulou P, Kanakoudi-Tsakalides F, Zaramboukas T, Vlachonikolis J. Clinical application of immunological markers as monitoring tests in celiac disease. Dig Dis Sci. 1999;44(10):2133-8. [pmid: 10548368].
398 Kaukinen K, Sulkanen S, Maki M, Collin P. IgA-class transglutaminase antibodies in evaluating the efficacy of gluten-free diet in coeliac disease. Eur J Gastroenterol Hepatol. 2002;14(3):311-5. [pmid: 11953698].
399 Bardella M T, Trovato C, Cesana B M, Pagliari C, Gebbia C, Peracchi M. Serological markers for coeliac disease: Is it time to change?. Dig Liver Dis. 2001;33(5):426-31. [pmid: 11529655].
400 Burgin-Wolff A, Gaze H, Hadziselimovic F, Huber H, Lentze M J, Nussle D, et al. Antigliadin and antiendomysium antibody determination for coeliac disease. Arch Dis Child. 1991;66(8):941-7. [pmid: 1819255].
401 Scalici C, Manzoni D, Licastro G, Varia F, Di Prima L, Vitali R. Reliability of EMA assay in the evaluation of gluten-free diet compliance in celiac patients during follow-up. Acta Med Mediterr. 2003;19(1):67-9.
402 Vahedi K, Mascart-Lemone F, Mary JY, Laberenne JE, Bouhnik Y, Morin MC, et al. Are Anti-Endomysial (AEM) and Anti-Transglutaminase (TTG) Antibodies Reliable Markers of Strict Diet Compliance in Adult Celiacs on a Gluten Free Diet (GFD)? Gastroenterology 2000;118(4 Suppl. 2 Part 1):AGA.
403 Martini S, Mengozzi G, Aimo G, Giorda L, Pagni R, Guidetti C S. Comparative evaluation of serologic tests for celiac disease diagnosis and follow-up. Clin Chem. 2002;48(6 Pt 1):960-3. [pmid: 12029021].
404 Valletta E A, Trevisiol D, Mastella G. IgA anti-gliadin antibodies in the monitoring of gluten challenge in celiac disease. J Pediatr Gastroenterol Nutr. 1990;10(2):169-73. [pmid: 2303968].
405 Wahab P J, Meijer Jos W R, Mulder Chris J J. Histologic follow-up of people with celiac disease on a gluten-free diet: slow and incomplete recovery. American Journal of Clinical Pathology. 2002;118(3):459-63. [pmid: 12219789].
406 McNicholl B, Egan-Mitchell B, Stevens F, Keane R, Baker S, McCarthy C F, et al. Mucosal recovery in treated childhood celiac disease (gluten-sensitive enteropathy). J Pediatr. 1976;89(3):418-24. [pmid: 956966].
407 Valentini R A, Andreani M L, Corazza G R, Gasbarrini G. IgA endomysium antibody: a valuable tool in the screening of coeliac disease but not its follow-up. Ital J Gastroenterol. 1994;26(6):279-82. [pmid: 7949263].
408 Fabiani E, Catassi C. The serum IgA class anti-tissue transglutaminase antibodies in the diagnosis and follow up of coeliac disease. Results of an international multi-centre study. International Working Group on Eu-tTG. Eur J Gastroenterol Hepatol. 2001;13(6):659-65. [pmid: 11434591].
409 Dickey W, Hughes D F, McMillan S A. Disappearance of endomysial antibodies in treated celiac disease does not indicate histological recovery. Am J Gastroenterol. 2000;95(3):712-4. [pmid: 10710062].
410 Fabiani E, Catassi C, Villari A, Gismondi P, Pierdomenico R, Ratsch I M, et al. Dietary compliance in screening-detected coeliac disease adolescents. Acta Paediatr. 1996;412:65-7.
411 Lee S K, Lo W, Memeo L, Rotterdam H, Green Peter H R. Duodenal histology in patients with celiac disease after treatment with a gluten-free diet. Gastrointest Endosc. 2003;57(2):187-91. [pmid: 12556782].
412 Pacht A, Sinai N, Hornstein L, Kumar V, Ish-Shalom N, Lerner A. The diagnostic reliability of anti-endomysial antibody in celiac disease: the north Israel experience. Isr J Med Sci. 1995;31(4):218-20. [pmid: 7721558].
413 Sategna-Guidetti C, Grosso S, Bruno M, Grosso S B. Reliability of immunologic markers of celiac sprue in the assessment of mucosal recovery after gluten withdrawal. J Clin Gastroenterol. 1996;23(2):101-4. [pmid: 8877634].
414 Selby W S, Painter D, Collins A, Faulkner-Hogg K B, Loblay R H. Persistent mucosal abnormalities in coeliac disease are not related to the ingestion of trace amounts of gluten. Scand J Gastroenterol. 1999;34(9):909-14. [pmid: 10522611].
415 Troncone R, Mayer M, Spagnuolo F, Maiuri L, Greco L. Endomysial antibodies as unreliable markers for slight dietary transgressions in adolescents with celiac disease. J Pediatr Gastroenterol Nutr. 1995;21(1):69-72. [pmid: 8576818].
416 Anson O, Weizman Z, Zeevi N. Celiac disease: parental knowledge and attitudes of dietary compliance. Pediatrics. 1990;85(1):98-103. [pmid: 2296499].
417 Fabiani E, Taccari L M, Ratsch I M, Di Giuseppe S, Coppa G V, Catassi C. Compliance with gluten-free diet in adolescents with screening-detected celiac disease: a 5-year follow-up study. J Pediatr. 2000;136(6):841-3. [pmid: 10839888].
418 Jackson P T, Glasgow J F, Thom R. Parents' understanding of coeliac disease and diet. Arch Dis Child. 1985;60(7):672-4. [pmid: 4026368].
419 Lamontagne P, West G E, Galibois I. Quebecers with celiac disease: analysis of dietary problems. Canadian Journal of Dietetic Practice and Research - a Publication of Dietitians of Canada = Revue Canadienne De La Pratique Et De La Recherche En Dietetique - Une Publication Des Dietetistes Du C. 2001;62(4):175-81.
420 Ljungman G, Myrdal U. Compliance in teenagers with coeliac disease--a Swedish follow-up study. Acta Paediatr. 1993;82(3):235-8. [pmid: 8495075].
421 Hogberg L, Grodzinsky E, Stenhammar L. Better dietary compliance in patients with coeliac disease diagnosed in early childhood. Scand J Gastroenterol. 2003;38(7):751-4. [pmid: 12889562].
422 Patin N M, Johnson F, Kirks B A. Promoting dietary compliance in gluten-intolerant children. J Nutr Educ. 1989;21(2):100D.
423 Lijmer JG, Mol BW, Heisterkamp S, Bonsel GJ, Prins MH, van der Meulen JH, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA 1999;282(11):1061–6. Available: PM:10493205.
424 Tursi A, Brandimarte G, Giorgetti G M. Prevalence of antitissue transglutaminase antibodies in different degrees of intestinal damage in celiac disease. Journal of Clinical Gastroenterology. 2003;36(3):219-21. [pmid: 14564185].
425 Tursi A, Brandimarte G, Giorgetti G, Gigliobianco A, Lombardi D, Gasbarrini G. Low prevalence of antigliadin and anti-endomysium antibodies in subclinical/silent celiac disease. American Journal of Gastroenterology. 2001;96(5):1507-10. [pmid: 11374690].
426 Tursi A, Brandimarte G, Giorgetti G M. Sorbitol H2-breath test versus anti-endomysium antibodies for the diagnosis of subclinical/silent coeliac disease. Scand J Gastroenterol. 2001;36(11):1170-2. [pmid: 11686216].
427 Demir H, Yuce A, Kocak N, Ozen H, Gurakan F. Celiac disease in Turkish children: presentation of 104 cases. Pediatrics International - Official Journal of the Japan Pediatric Society. 2000;42(5):483-7. [pmid: 11059535].
428 Kotze Lorete Maria da Silva, Utiyama Shirley Ramos da Rosa, Nisihara R M, de C V, Ioshii S O. IgA class anti-endomysial and anti-tissue transglutaminase antibodies in relation to duodenal mucosa changes in coeliac disease. Pathology. 2003;35(1):56-60. [pmid: 12701686].
429 Sategna-Guidetti C, Bruno M, Pulitano R, Ferfoglia G. Disease specificity of IgA class anti-endomysium antibodies (IgA-EmA) in adult coeliac disease. Eur J Gastroenterol Hepatol. 1991;3(3):251-4.
430 Ciacci C, Cavallaro R, Della V N, D'argenio G. The Use of Serum Ttg-Ab Assay in Patients on Gluten-Free Diet as a Measure of Dietetic Compliance. Gastroenterology. 2002;122(2):588. [pmid: 11845804].
431 Garcia V E, De Lourdes de Abreu Ferrari, Alves B E, Affonso Barbosa A J, Brasileiro F G, Hartung T N, et al. Agreement between pathologists concerning assessment of intestinal biopsies from adult celiac disease patients. Gastroenterol Int. 2002;15(12):1-8.
432 Weile B, Hansen B F, Hagerstrand I, Hansen J P, Krasilnikoff P A. Interobserver variation in diagnosing coeliac disease. A joint study by Danish and Swedish pathologists. Apmis - Acta Pathologica, Microbiologica, Et Immunologica Scandinavica. 2000;108(5):380-4. [pmid: 10937777].
433 Landis JR, Koch GG. The measurement of observer agreement for categorical data. Biometrics 1977;33(1):159–74. Available: PM:843571.
434 Risdon R A, Keeling J W. Quantitation of the histological changes found in small intestinal biopsy specimens from children with suspected coeliac disease. Gut. 1974;15(1):9-18. [pmid: 4820632]. [pmcid: 1412946].
435 Glasgow J F, Corkey C W, Molla A. Critical assessment of small bowel biopsy in children. Archives of Disease in Childhood. 1979;54(8):604-8. [pmid: 507914].
436 Jarvinen T T, Kaukinen K, Laurila K, Kyronpalo S, Rasmussen M, Maki M, et al. Intraepithelial lymphocytes in celiac disease. American Journal of Gastroenterology. 2003;98(6):1332-7. [pmid: 12818278].
437 Corazza GR, Bonvicini F, Frazzoni M, Gatto M, Gasbarrini G. Observer variation in assessment of jejunal biopsy specimens. A comparison between subjective criteria and morphometric measurement. Gastroenterology 1982;83(6):1217–22. Available: PM:7129029.
438 Stenhammar L, Brandt A, Wagermark J. A family study of coeliac disease. Acta Paediatr Scand 1982;71(4):625–8. Available: PM:7136679.
439 Troncone R, Catassi C, Lambertini A, Zaniboni M G, Lazzari R, Bottaro G, et al. Latent coeliac disease in Italy. Acta Paediatr Int J Paediatr. 1995;84(11):1252-7.
440 Maki M, Lahdeaho ML, Hallstrom O, Viander M, Visakorpi JK. Postpubertal gluten challenge in coeliac disease. Arch Dis Child 1989;64(11):1604–7. Available: PM:2604420.
441 Schmitz J, Arnaud-Battandier F J J, Rey J. Long term follow-up of childhood coeliac disease (CD): Is there a “natural recovery”?. Pediatr Res. 1984;18:1052.
442 Ferguson A, McClure J P, Townley R R. Intraepithelial lymphocyte counts in small intestinal biopsies from children with diarrhoea. Acta Paediatrica Scandinavica. 1976;65(5):541-6. [pmid: 961407].
443 Kutlu T, Brousse N, Rambaud C, Le Deist F, Schmitz J, Cerf-Bensussan N. Numbers of T cell receptor (TCR) alpha beta+ but not of TcR gamma delta+ intraepithelial lymphocytes correlate with the grade of villous atrophy in coeliac patients on a long term normal diet. Gut. 1993;34(2):208-14. [pmid: 8432475]. [pmcid: 1373972].
444 O'Farrelly C, Graeme-Cook F, Hourihane D O, Feighery C, Weir D G. Histological changes associated with wheat protein antibodies in the absence of villous atrophy. Journal of Clinical Pathology. 1987;40(10):1228-30. [pmid: 3680547]. [pmcid: 1141200].
445 Saputo V, Losi S, Mancosu M, Della Morte M A, Moschettini G F. Intraepithelial lymphocytes in jejunal mucosa: diagnostic significance of changes in their number during chronic intestinal disease, with particular reference to coeliac disease. Schweizerische Rundschau Fur Medizin Praxis = Revue Suisse De Medecine Praxis. 1981;70(30):1342-8. [pmid: 7267614].
446 Mino M, Lauwers G Y. Role of lymphocytic immunophenotyping in the diagnosis of gluten-sensitive enteropathy with preserved villous architecture. Am J Surg Pathol. 2003;27(9):1237-42. [pmid: 12960808].
447 Goldstein N S, Underhill J. Morphologic features suggestive of gluten sensitivity in architecturally normal duodenal biopsy specimens. American Journal of Clinical Pathology. 2001;116(1):63-71. [pmid: 11447753].
448 Kuitunen P, Kosnai I, Savilahti E. Morphometric study of the jejunal mucosa in various childhood enteropathies with special reference to intraepithelial lymphocytes. Journal of Pediatric Gastroenterology and Nutrition. 1982;1(4):525-31. [pmid: 7186067].
449 Kaukinen K, Collin P, Holm K, Karvonen A L, Pikkarainen P, Maki M. Small-bowel mucosal inflammation in reticulin or gliadin antibody-positive patients without villous atrophy. Scandinavian Journal of Gastroenterology. 1998;33(9):944-9. [pmid: 9759950].
450 Wahab P J, Crusius J B, Meijer J W, Mulder C J. Gluten challenge in borderline gluten-sensitive enteropathy. American Journal of Gastroenterology. 2001;96(5):1464-9. [pmid: 11374684].
451 Wahab P J, Meijer Jos W R, Dumitra D, Goerres M S, Mulder Chris J J. Coeliac disease: more than villous atrophy. Romanian Journal of Gastroenterology. 2002;11(2):121-7. [pmid: 12145668].
452 Mahadeva S, Wyatt J I, Howdle P D. Is a raised intraepithelial lymphocyte count with normal duodenal villous architecture clinically relevant?. Journal of Clinical Pathology. 2002;55(6):424-8. [pmid: 12037023]. [pmcid: 1769667].
453 Kaukinen K, Maki M, Partanen J, Sievanen H, Collin P. Celiac disease without villous atrophy: revision of criteria called for. Dig Dis Sci. 2001;46(4):879-87. [pmid: 11330428].
454 Catassi C, Fabiani E, Corrao G, Barbato M, De Renzo A, Carella A M, et al. Risk of non-Hodgkin lymphoma in celiac disease. JAMA. 2002;287(11):1413-9. [pmid: 11903028].
455 Johnston S D, Watson R G P. Small bowel lymphoma in unrecognized coeliac disease: A cause for concern?. Eur J Gastroenterol Hepatol. 2000;12(6):645-8. [pmid: 10912485].
456 Green P H R, Stavropoulos S N, Panagi S G, Goldstein S L, Mcmahon D J, Absan H, et al. Characteristics of adult celiac disease in the USA: results of a national survey. Am J Gastroenterol. 2001;96(1):126-31. [pmid: 11197241].
457 Wahab P J, Meijer Jos W R, Mulder C J J. Histologic follow-up of people with celiac disease on a gluten-free diet: slow and incomplete recovery. Am J Clin Pathol. 2002;118(3):459-63. [pmid: 12219789].
458 Goerres M S, Meijer J W R, Wahab P J, Kerckhaert J A M, Groenen P J T A, Van Krieken J H J M, et al. Azathioprine and prednisone combination therapy in refractory coeliac disease. Aliment Pharmacol Ther. 2003;18(5):487-94. [pmid: 12950421].
459 Cellier C, Delabesse E, Helmer C, Patey N, Matuchansky C, Jabri B, et al. Refractory sprue, coeliac disease, and enteropathy-associated T-cell lymphoma. French Coeliac Disease Study Group. Lancet. 2000;356(9225):203-8. [pmid: 10963198].
460 Ciacci C, Cirillo M, Cavallaro R, Mazzacca G. Long-term follow-up of celiac adults on gluten-free diet: prevalence and correlates of intestinal damage. Digestion. 2002;66(3):178-85. [pmid: 12481164].
461 Kluge F, Koch H K, Grosse-Wilde H, Lesch R, Gerok W. Follow-up of treated adult celiac disease: clinical and morphological studies. Hepatogastroenterology. 1982;29(1):17-23. [pmid: 7095732].