# Acknowledgments

## Author Contribution

Dr. Alaa Rostom was the lead investigator. He was involved in all aspects of the study design, management, planning, analysis and write-up, including article screening, data extraction, quality assessment, statistical analysis, and report write-up. Drs. Catherine Dubé and Ann Cranney were the second investigators. Dr. Catherine Dubé was involved in all aspects of study design, and planning and organization, including task management, article screening, data extraction, and quality assessment. She was the lead writer of Celiac 2 and 3. Dr. Ann Cranney was involved in all aspects of study design and planning, including article screening, data extraction, and quality assessment. She was the lead writer of Celiac 4, and oversaw the screening and data extraction for Celiac 3, 4, and 5. Dr. Navaaz Saloojee was involved in study planning, article screening, data extraction, and quality assessment, and was the lead writer of Celiac 5. Dr. Richmond Sy was involved in study planning, article screening, data extraction, and contributed to the writing of Celiac 4. Drs. David Mack and Dilip Patel were involved in study planning and article screening, in addition to being content experts in pediatric and adult celiac disease, respectively. They also reviewed and advised on the report write-up. JoAnne McNeal was involved in article screening and data extraction for Celiac 1 (serology) and Celiac 2 (prevalence).

Dr. David Moher was involved in all aspects of study design, management, planning, analysis, and write-up. He was the methodological content expert and reviewed and advised on all report conduct and documents. Chantelle Garrity was involved in all aspects of project planning and management, including liaison with all key partners. She oversaw the screening progress, document retrieval, and assisted in report management, review and write-up. Margaret Sampson was the lead information specialist and was involved in all aspects of the search strategy/key word design and refinement, in association with the information specialists at the NLM. She was involved in all aspects of article database management, including article retrieval, set-up of the online computerized SRS article screening and extraction system, and the development and write-up of the QUOROM Flow. Li Zhang was the information specialist involved in all aspects of SRS system management, article retrieval, and implementation of the SRS system. Dr. Vasil Mamaladze and Fatemeh Yazdi performed the data extraction of Celiac 1-serology and Celiac 2-prevalence. Irene Pan performed data extraction and quality assessment of Celiac 2-prevalence.