# Appendix I. Evidence Tables

List of abbreviations used in the evidence tables

Ab=antibody
AGA=anti-gliadin antibodies
ARA=antireticulin antibodies
Bx=biopsy
CD=celiac disease
CI=confidence interval
CO=control
Dx=diagnosis
EGD=esophagogastroduodenoscopy
EIA=enzyme immunoassay
EMA=anti-endomysium antibodies
F=female
GC=gluten challenge
GCD=gluten-containing diet
GERD=gastroessophageal reflux disease
GFD=gluten-free diet
GI=gastrointestinal
GP=guinea pig
Hb-hemoglobin
HLA=human leukocyte antigens
HU=human umbilical cord
HUVEC=human umbilical vein endothelial cells
JAB=human jejunal antibodies
IBS=irritable bowel syndrome
IDA=iron deficiency anemia
IDDM=insulin-dependent diabetes mellitus
IF=immunofluorescence
M=male
ME=monkey esophagus
mos=months
n=number of patients
n/a=not applicable
NHL=non-Hodgkin's lymphoma
n/r=not reported
OR=odds ratio
pt=patient
RR=relative risk
SD=standard deviation
TGA=anti-thyroglobulin
tTG=anti-tissue transolutaminase
UTCD=untreated celiac disease
VA=villous atrophy
y=year

## Celiac 1: Sensitivity and Specificity of Tests for CD

### Serology

Evidence Table 1. Included studies of the sensitivity and specificity of serology for CD

Author, year, Location | Study Design | Study Population | Control Population | Results
| | | | | 4×4 table
| | | | Comparison | a | c | b | d | Sens | Spec | PPV | NPV
Altuntas, 1998 Turkey | Publication type: | Celiac Group 1 | Group 1: | celiac 1 vs control 1 IgA AGA | 6 | 20 | 2 | 19 | 23 | 90 | 75 | 48
| •journal | • 26 short-statured children with probable CD on biopsy | •21 short-statured children without CD on biopsy; | celiac 1 vs control 1 IgG AGA | 26 | 0 | 21 | 0 | 100 | 0 | 55 | 0
| Study design: | • mean age: n/r | •median age: n/r
| • cohort | • % F: n/r | • % F: n/r
| Ethnicity:
| • n/a
| Population Type:
| • n/a
| Reference test:
| • endoscopic biopsy
| First test:
| • serology test
| Controls biopsied:
| • yes
| Biopsy criteria:
| • subtotal or total VA, crypt hyperplasia, increased IEL
| Checked IgA def.
| • n/r
| Studied tests
| • IgA-AGA
| • IgG-AGA
| Methodology:
| • ELISA
| Cut-off:
| • levels between 25 and 50 RU/mL were accepted as weakly positive and levels >50 RU/mL as strongly positive
Artan, 1998, Turkey | Publication type: | Celiac Group 1 | Group 1: | celiac 1 vs control 1-IgA-AGA | 14 | 10 | 19 | 20; | 58 | 51 | 42.4 | 66.7
| • journal | • 24 children with CD by ESPGAN, out of 63 suspected CD pts | • 39 of 63 with normal intestinal villous structure. | celiac 1 vs control 1-IgG-AGA | 20 | 4 | 16; | 23 | 83 | 59 | 55.6 | 85.2
| Study design: | • age: n/r | • Age: n/r | IgA AND IgG | 12 | 12 | 13; | 26 | 50 | 67 | 48 | 68.4
| • cohort | • % F: n/r | • % F: n/r | IgA OR IgG | 20 | 4 | 25; | 14 | 83 | 36 | 44 | 77.8
| Ethnicity:
| • n/a
| Population Type:
| • n/a
| Reference test:
| • biopsy
| First test:
| • simultaneous
| Controls biopsied:
| • yes
| Biopsy criteria:
| • ESPGAN
| Checked IgA def.
| • n/r
| Studied tests
| IgA-AGA; IgG-AGA; IgA and IgG; IgA or IgG
| Methodology:
| • ELISA
| Cut-off:
| •>25 arbitrary units (did not adjust for age)
Ascher, 1996 Sweden | Publication type: | Celiac Group 1 | Group 1: | group 1 vs control, EIA IgA | 50 | 5 | 1 | 64 | 90.9 | 98.5
| • journal | • 55 pts with biopsy proven CD | • 65 disease controls with biopsy proven normal intestinal mucosa; | group 1 vs control, EIA IgG | 53 | 2 | 20 | 45 | 96.4 | 69.2
| Study design: | • mean age: n/r; <5 y n=22; >5 y n=33 | • mean age: n/r; <5 y n=18; >5 y n=47 | group 1 vs control, DIG-ELISA IgA | 50 | 5 | 2 | 63 | 90.9 | 96.9
| • cohort | • % female: n/r | • % female: n/r | group 1 vs control, DIS-ELISA IgA | 48 | 7 | 9 | 56 | 87.3 | 86.2
| Ethnicity: | Celiac Group 2 | | group 1 vs control ARA | 48 | 6 | 18 | 47 | 88.9 | 72.3
| • n/a | • 36 out of initial 55 pts who were treated with GFD of 1 y; | | group 1 vs control, Human JAB | 55 | 0 | 18 | 47 | 100 | 72.3
| Population Type: | • mean age: n/r; <5 y n=21; >5 y n=15 | | group 1 vs control, RAT JAB | 55 | 0 | 11 | 54 | 100 | 83.1
| • n/a | • % female: n/r | | group 1 vs control, EMA | 54 | 1 | 0 | 65 | 98.2 | 100
| Reference test: | Celiac Group 3 | | group 3 vs control, EIA IgA | 20 | 1 | 1 | 64 | 95.5 | 98.5
| • n/r | • 21 pts on a gluten-challenge diet of 3–6 mos | | group 3 vs control, EIA IgG | 19 | 2 | 20 | 45 | 90.5 | 69.2
| First test: | • mean age: n/r; <5 y n=18; >5 y n=3; | | group 3 vs control, DIG-ELISA IgA | 17 | 4 | 2 | 63 | 80.9 | 96.9
| • biopsy and serum tests obtained simultaneously | • % female: n/r | | group 3 vs control, DIS-ELISA IgA | 15 | 5 | 9 | 56 | 75 | 86.1
| Controls biopsied: | NB: | | group 3 vs control, ARA | 18 | 3 | 18 | 47 | 85.7 | 72.3
| • yes | group 2: biopsy proven CD on a GFD of > 1 y; | | group 3 vs control, Human JAB | 21 | 0 | 18 | 47 | 100 | 72.3
| Biopsy criteria: | group 3: biopsy proven CD on a gluten challenge of 3–6 mos duration | | group 3 vs control, RAT JAB | 18 | 3 | 11 | 54 | 85.7 | 83
| • ESPGAN | | | group 3 vs control, EMA | 19 | 2 | 0 | 65 | 90.5 | 100
| Checked IgA def.
| • Yes
| Studied tests
| • EIA IgA; EIA IgG; DIG-ELISA IgA; DIG-ELISA IgG; ARA; Human JAB; Rat JAB; EMA
| Methodology:
| for EIA IgA and IgG: ELISA; for ARA: IF; for EMA, JAB: immunohistochemical method
| Cut-off:
| EIA IgA and IgG: 35 AU (arbitrary units) for children <5 y; and 20 AU for children >5 y; DIG-ELISA: IgA values >13 mm and IgG values >16 mm were considered positive in children <5 y; IgA values <11 mm and IgG values >14 mm - in children >5 y
Ascher, 1990 Sweden | Publication type: | Celiac Group 1 | Group 1: | group 1 vs control PG IgA-EIA | 35 | 1 | 7 | 85 | 97 | 92 | 83.3 | 98.8
| • journal | • 36 pts with CD out of 130 consecutive group of children who had a small intestinal biopsy due to symptoms suggestive of CD; out of 36 pts with CD, 28 have been verified according to ESPGAN criteria; | • 92 children taken from consecutive group of 130 children who did not have CD; 12 had other food intolerance, 1 had cystic fibrosis and 79 had no intestinal disorder
| Study design: | • mean age: n/r
| • cohort | • % female: n/r
| Ethnicity: | Celiac Group 2
| • n/a | • children with CD according to ESPGAN's criteria, differing with regard to gluten content of diet: first biopsy on a gluten-containing diet (n=29); at the second biopsy after 1 y on GFD (n=45); at the third biopsy after gluten-challenge (n=45);
| Population Type: | • mean age: n/r
| • n/a | • % F: n/r
| Reference test: | Celiac Group 3
| • Watson capsule | • children with an initial abnormal mucosa that normalized on a GFD but did not relapse after gluten challenge during 3–31 mos
| First test: | • mean age: n/r
| • biopsy and serum tests obtained simultaneously | • % F: n/r
| Controls biopsied:
| • yes
| Biopsy criteria: ESPGAN
| Checked IgA def. Yes
| Studied tests
| • Pharmacia Gluten IGA-AGA measured by enzyme immunoassay (PG IGA-EIA)
| Methodology:
| • ELISA
| Cut-off:
| • 35 AU (arbitrary units)
Bahia, 2001 Brazil | Publication type: | Celiac Group 1 | Group 1: | IgA group 1 vs CO | 21 | 1 | 2 | 46 | 95.5 | 95.6 | when prevalence is 1:500 PPV for IgA is 4.8%; in prevalence of 1:1000 PPV=2.0; in prevalence of 1:2000, PPV=1.1 | in any prevalence of CD NPV for IgA is 99.9%
| • journal | • 22 pts with CD | • 46 controls with biopsy-proven non-CD enteropathies (CO) | IgA group 1 vs OE+CO | 21 | 1 | 9 | 98 | 95.5 | 91.6
| Study design: | • age (mos): mean/SD: 30.6+/-28.8; | • age (mos): mean/SD: 96.9+/-48.5; median w/range: 92.6 (12.2–170.8); | IgG group 1 vs CO | 20 | 2 | 1 | 45 | 90.9 | 97.8
| • cohort | • % F: 54.5 | • % F: 54.5 | IgG group 1 vs OE+CO | 20 | 2 | 12 | 95 | 90.9 | 88.7
| Ethnicity: | • median w/range: 19.3 (6.0–135.6)
| • n/a | • % female: 54.5
| Population Type: | Celiac Group 2
| • suspected CD | • 61 pts with other enteropathies (OE);
| Reference test: | • age (mos): mean/SD: 43.3+-38.1;
| • Carey capsule | • median w/range: 27.9 (4.8–156.5);
| First test: | • % F: 59
| • n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| • severe VA
| Checked IgA def.
| • n/r
| Studied tests
| • IgA and IgG-AGA
| Methodology:
| • ELISA
| Cut-off:
| • mean+2 SD for a group of 20 normal children: 0.022 for IgA (mean=0.0065, SD=0.0076); and 0.103 for IgG (mean=0.0393, SD=0.032)
Bardela, 2001 Italy | Publication type: | Celiac Group 1 | Group 1: | AGA group 1 vs CO | 38 | 2 | 12 | 98 | 95 | 89 | when expected prevalence is 0.5%, PPV for AGA is 4.2%; for EMA - 15.7% and for tTGA - 21.8%; when expected prevalence of CD is 50%, PPV for AGA is 89.7%, for EMA - 97.4% and for tTGA - 98.2% | when expected prevalence is 0.5%, NPV for AGA is 99.9%; for EMA - 100% and for tTGA - 100%; when expected prevalence of CD is 50%, NPV for AGA is 94.7%, for EMA - 100% and for tTGA - 100%
| • journal | • 40 untreated biopsy-proven CD pts | • 110 biopsy proven non-CD disease controls (CO): inflammatory bowel disease (n=22); IBS (n=29); peptic ulcer (n=7); diverticular disease (n=6); pancreatitis (n=5); non- ulcer dyspepsia(n=14); anemia not due to malabsorption (n=7); reflux esophagitis (n=3); atrophic gastritis (n=2); acute appendicitis (n=1) | EMA group 1 vs CO | 40 | 0 | 3 | 107 | 100 | 97.2
| Study design: | • age (y): mean 38, range 16–77 | • age (y): mean 41, range 14–80 | tTGA group 1 vs CO | 40 | 0 | 2 | 108 | 100 | 98.2
| • cohort | • % F: 72.5 | • % F: 75.7;
| Ethnicity: | Celiac Group 2
| • n/a | • 195 treated CD pts; biopsy proven on GFD
| Population Type: | • age (y): mean 38, range 16–79
| • suspected CD | • % F: 70.2
| Reference test:
| • endoscopic biospy
| First test:
| • n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| • Marsh, no grade reported
| Checked IgA def.
| • Yes and excluded
| Studied tests
| • IgA-AGA; IgA-EMA; IgA-tTGA
| Methodology:
| • ELISA for AGA; ELISA for tTGA GP liver; IF for EMA ME
| Cut-off:
| • AGA: 12 AU/mL; tTGA: >10 AU/mL; EMA: antibody titre > 1:10
Berger, 1996 Switzerland | Publication type: | Celiac Group 1 | Group 1 (CO): | CD vs CO
| • journal | • 67 biopsy proven CD pts | • 54 biopsy proven non-CD pts: transient GI problems (n=39), ulcerative colitis (n=2), Crohn's disease (n=8), duodenal ulcer (n=3), short stature (n=2) | Eurospital IgG | 55 | 12 | 27 | 27 | 82 | 50 | 67 | 69
| Study design: | • age: n/r | • age: n/r | FIST IgG | 56 | 11 | 53 | 1 | 84 | 2 | 51 | 8
| • case-control | • % F: n/r | • % F: n/r | Granditsch IgG | 55 | 12 | 46 | 8 | 82 | 15 | 54 | 36
| Ethnicity: | | | Labodia IgG | 61 | 6 | 42 | 12 | 91 | 22 | 59 | 57
| • n/a | | | Pharmacia IgG | 46 | 21 | 22 | 32 | 69 | 59 | 68 | 53
| Population Type: | | | Eurospital IgA | 41 | 26 | 3 | 51 | 61 | 94 | 93 | 57
| • suspected CD | | | FIST IgA | 44 | 23 | 49 | 5 | 66 | 9 | 47 | 17
| Reference test: | | | Granditsch IgA | 53 | 14 | 23 | 31 | 79 | 57 | 70 | 59
| • endoscopic biopsy | | | Labodia IgA | 58 | 9 | 35 | 19 | 87 | 35 | 62 | 58
| First test: | | | Pharmacia IgA; | 51 | 16 | 18 | 36 | 76 | 67 | 74 | 59
| • n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| • ESPGAN revised with complete VA
| Checked IgA def.
| • n/r
| Studied tests
| • 5 different AGA assays: Eurospital; Labodia; Pharmacia; FIST-IF; Granditsch; IgA EMA
| Methodology:
| • for AGA - ELISA; for EMA - IF
| Cut-off:
| For IgG Eurospital: index30–50; in Pharmacia units: 30–50 AU; Labodia: 30 U/mL; in Pharmacia units-18; Pharmacia: 20–100 AU; FIST: titer 1:20; in Pharmacia units-13 AU; Granditsch: 0.350 OD; in Pharmacia units: 70 AU; for IgA Eurospital: index 8–20; in Pharmacia units: 53–132 AU; Labodia: 15 U/mL; in Pharmacia units-28; Pharmacia: 20–35 AU; FIST: titer 1:20; in Pharmacia units-34 AU; Granditsch: 0.250 OD; in Pharmacia units: 38 AU
Biagi, 2001 Italy | Publication type: | Celiac Group 1 | Group 1: | IgA TTG group 1 vs CO when considering borderline results as positive | 55 | 1 | 8 | 44 | 98.2 | 84.6 | 87.3 | 97.7
| • journal | • 56 pts with biopsy-proven CD | • 52 disease controls (biopsy-proven non-SD enteropathies) with irritable bowel disease (n=29); Crohn's disease (n=9); gastric lymphoma (n=7); Whipple disease (n=3); giardiasis (n=2); systemic mastocytosis (n=1); IgE-mediated food sensitivity | IgA-tTG group 1 vs CO when considering borderline results as negative | 49 | 7 | 1 | 51 | 87.5 | 98.1 | 98 | 87.9
| Study design: | • age (y): mean/SD: 39.2+-19.2; range 4–79 | • mean age (y): 40.4+-19.9; range 14–79; | IgA EMA group 1 vs CO | 53 | 3 | 0 | 52 | 94.6 | 100 | 100 | 94.5
| • case-control | • % F: 76 | • % F:
| Ethnicity:
| • n/a
| Population Type:
| • n/a
| Reference test:
| • Carey capsule
| First test:
| • n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| • partial VA or greater
| Checked IgA def.
| • Only in EMA (neg) pts in CD group
| Studied tests
| • IgA-tTG
| • IgA-EMA
| Methodology:
| • TTG-GP; EMA -ME
| Cut-off:
| • on the basis of ROC analysis performed on the preliminary results (group of 30 controls) results >0.65 OD (optical density) were considered positive; <0.35 OD - negative and 0.35–0.65 OD - borderline
Bode, 1993 Denmark | Publication type: | Celiac Group 1 | Group 1: | group 1 vs control 1, serum AGA-IgA; in brackets data according to new cut off | | | | | 64 (79) | 99 (98) | 90 (79) | 97 (98)
| • journal | • 14 of 233 consecutive children with untreated CD | • 177 children with non-CD diseases: postenteritis diarrhea (n=43), short stature (n=25), diarrhea (n=25), failure to thrive (n=22), food allergy (n=11), dissaccharide intolerance (n=8), dietary problems (n=8), giardiasis (n=4), ulcerative colitis (n=3), recurrent abdominal pain (3), constipation (n=2), recurrent infections (n=2), acute gastroenteritis (n=1), Crohn's disease (n=1), other GI diseases (n=4), other non-GI diseases (n=15) | group 1 vs control 1, serum AGA-IgG; in brackets data according to new cut off limits | | | | | 71 (93) | 99 (98) | 100 (76) | 98 (99)
| Study design: | • median age for the 233: 2.75; range 0.33–15.5) | Group 2: | group 1 vs control 1, serum AGA-IgA/IgG; in brackets data according to new cut-off limits | | | | | 86 (100) | 99 (97) | 92 (70) | 99 (100)
| • cohort | • 117 males; 74 females | • 8 children not CD/GFD and gluten challenge
| Ethnicity: | Celiac Group 2a | • age (y): median 2.5, range 1.17–7.5
| • n/a | • T-CD - group 2a) 47 children with CD on GFD | • % F: 37.5
| Population Type: | • age (y): median 11.83, range 1–17.92
| • n/a | • % F: 61.7
| Reference test: | Celiac Group 2b
| • n/r | • 14 children with known CD on gluten challenge
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| • typical biopsy and response to a GFD (likely ESPGAN)
| Checked IgA def.
| • yes
| Studied tests
| • serum IgG-AGA
| • serum IgA-AGA
| Methodology:
| • DIG-ELISA - diffusion in gel ELISA
| Cut-off:
| • 1) old limits: positive test for IgA AGA was defined as >10.5 mm and/or IgG level >14 mm; 2) new limits for children: for IgA >10 mm and for IgG >13 mm
Bode, 1994 Denmark | Publication type: | Celiac Group 1 | Group 1: | group 1 IgA-AGA | | | | | 46 | 98 | 75 | 92
| • journal | • 100 consecutive adult pts admitted for a small intestinal biopsy on suspicion of CD | • 87 out of 100 suspected of CD who did not have CD by biopsy | group 1 IgG-AGA | | | | | 62 | 97 | 73 | 94
| Study design: | • age (y): median 51, range 17–81 | | group 1 IgA/IgG-AGA | | | | | 77 | 95 | 71 | 97
| • cohort | • % F: 64; [underlined: 13 CD pts]
| Ethnicity: | Celiac Group 2
| • n/a | • 118 adult pts with increased or borderline (gliadin antibodies) AGA
| Population Type: | • age (y): median 48, range 19–95
| • n/a | • % F: 72;
| Reference test: | • 55 children pts with increased or borderline (gliadin antibodies) AGA
| • n/r | • age (y): median 4, range 7 mos-17
| First test: | • % F: 56
| • n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| • Crypt hyperplasia, VA and increase inflammatory cells
| Checked IgA def.
| • n/r
| Studied tests
| • serum IgG-AGA
| • serum IgA-AGA
| Methodology:
| • DIG-ELISA - diffusion in gel ELISA
| Cut-off:
| • positive test for IgA AGA was >10.5 mm; for IgG - >14 mm; borderline levels for IgA was between 9.5 mm and 10.5 mm; and for IgG - between 13 mm and 14 mm
Bonamico, 2001 Italy | Publication type: | Celiac Group 1 | Group 1: | RIA group 1 vs control | 62 | 0 | 0 | 56 | 100 | 100 | 100 | 100
| • journal | • 62 pts; untreated with biopsy-proven celiac CD | • 56 disease controls; chronic diarrhea, short stature, recurrent abdominal pain; age and sex-matched controls | RIA group 2 vs control | 34 | 44 | 0 | 56 | 43.5 | 100 | 100 | 56
| Study design: | • median age 7, age range 1–23 | • median age, age range | RIA group 3 vs control | 14 | 0 | 0 | 14 | 100 | 100 | 100 | 100
| • case control | • % F: n/r | • % F: n/r | ELISA group 1 vs control | 56 | 6 | 0 | 56 | 90.3 | 100 | 100 | 90.3
| Ethnicity: | Celiac Group 2 | | ELISA group 2 vs control | 7 | 71 | 0 | 56 | 9.8 | 100 | 100 | 44
| • n/a | • 78 pts; GFD treated, at least 6 mos | | ELISA group 3 vs control | 11 | 3 | 0 | 56 | 78.5 | 100 | 100 | 94.9
| Population Type: | • median age, age range | | IF-EMA group 1 vs control | 59 | 3 | 1 | 55 | 95.1 | 98.2 | 98.3 | 94.8
| • n/a | • % F: n/r | | IF-EMA group 2 vs control | 9 | 69 | 1 | 55 | 11.5 | 98.2 | 90 | 44.3
| Reference test: | Celiac Group 3 | | IF-EMA group 3 vs control | 13 | 69 | 1 | 55 | 92.8 | 98.2 | 92.8 | 98.2
| • biopsy | • 14 pts; on gluten-challenge at least 3 mos
| First test: | • median age, age range
| • biopsy | • % F: n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| • ESPGAN (severe VA and crypt hyperplasia)
| Checked IgA def.
| • Yes
| Studied tests
| • tTG-HR (RIA)
| • tTG-GP (ELISA)
| • IF-EMA
| Methodology:
| • tTG-HR
| • tTG-GP
| • EMA-ME IF
| Cut-off:
| • RIA anti-tTG Ab ≥0.05 index as selected on ROC plot analysis; ELISA anti-tTG Ab ≥7 AU; IF-EMA - n/r (appearance of fluorescence)
Bottaro, 1997 Italy | Publication type: | Celiac Group 1 | Group 1: | group 1 vs control 1, serum AGA IgA | 46 | 4 | 8 | 17 | 92 | 68 | 85.2 | 80.9;
| • journal | • 50 children with biopsy proven CD | • 25 control group of children (CO) | group 1 vs control 1, serum AGA IgG | 50 | 0 | 16 | 9 | 100 | 36 | 75.7 | 100
| Study design: | • age: median 2.5 y, range 7 mos - 15 y | • age: median 3.0 y, range 9 mos - 14 y | group 1 vs control 1, serum EMA-IgA, HUC | 47 | 3 | 0 | 25 | 94 | 100 | 100 | 89.2
| • case-control | • % F: 68 | • % F: 52 | group 1 vs control 1, serum EMA-IgA, ME | 48 | 2 | 1 | 24 | 96 | 96 | 97.9 | 92.3
| Ethnicity: | | | group 1 vs control 1, serum ARA IgA
| • n/a
| Population Type:
| • n/a
| Reference test:
| • n/r
| First test:
| • n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| • ESPGAN
| Checked IgA def.
| • Yes
| Studied tests
| serum AGA-IgG
| serum AGA-IgA
| serum EMA-IgA
| serum ARA-IgA
| Methodology:
| • for AGA ELISA; for AGA-IgA IF; for EMA-IgA IF using ME or HU
| Cut-off:
| • AGA: for IgA 10% and for IgG 25%, resulting the mean+-SD of values obtained from children proven normal
Carroccio 2002 Italy | Publication type: | Celiac Group 1 | Group 1: | group 1 vs control 1, serum AGA IgG | 69 | 22 | 25 | 75 | 76 | 75 | 73.4 | 77.3
| • journal | • 91 pts with biopsy proven CD | • 100 subjects with a normal intestinal morphology or diseases other than CD (biopsy proven) | group 1 vs control 1, serum AGA IgA | 61 | 30 | 10 | 90 | 67 | 90 | 86 | 75
| Study design: | • age (y): median 2; range 7 mos - 84 y | • age (y): median 21 y, range 9 mos-76 y | group 1 vs control 1, serum EMA | 80 | 11 | 1 | 99 | 88 | 99 | 98.7 | 90
| • case-control | • % F: 56 | • % F: 56 | group 1 vs control 1, culture EMA | 82 | 9 | 0 | 100 | 90 | 100 | 100 | 91.7
| Ethnicity: | Celiac Group 2 | Group 2: | group 1 vs control 1, culture EMA+gliadin | 87 | 4 | 0 | 100 | 96 | 100 | 100 | 96
| • n/a | • 21 treated CD pts on a GFD with normal intestinal architecture | • 22 disease controls (biopsy-proven non-CD) with GERD-like symptoms | group 2 vs control 2, culture EMA+gliadin | 10 | 11 | 0 | 22 | 47.6 | 100 | 100 | 66.7
| Population Type: | • age (y): median 5, range 3–51 | • age (y): median 33, range 4–60
| • suspected CD | • % F: 62 | • % F: 54.5
| Reference test:
| children: Crosby capsule; adults: endoscopic biopsy
| First test:
| • n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| Marsh; CD was diagnosed as enlarged crypts and/or VA - with normalization on GFD
| Checked IgA def.
| • Yes
| Studied tests
| Serum AGA-IgG; Serum AGA-IgA; Serum EMA; Culture EMA; Culture EMA+gliadin
| Methodology:
| ELISA for AGA; indirect IF on ME for serum EMA; biopsy specimen incubation in a culture medium with gliadin peptide and further IF on ME
| Cut-off:
| AGA-results expressed as a % of reference serum: 20% was upper normal limit for IgG and 10% for IgA antibodies; EMA-semi-quantified as follows: 0=not detectable; 1=positive at dilutions between 1/5 and 1/20; 2=positive between 1/40 and 1/80; 3=positive at 1/100; 4=positive at 1/200; 5=positive at >1/200; EMA in culture-same as serum EMA and for IgG 25%, resulting the mean+-SD of values obtain ed from children proven normal
Carroccio 1993 Italy | Publication type: | Celiac Group 1 | Group 1: | celiac 1 vs control | 31 | 14 | 5 | 55 | 68 | 91.7 | 86.1 | 79.7
| • journal | • infants with CD on gluten diet; biopsy proven | • 60 infants disease controls; biopsy proven non-CD | | 40 | 5 | 32 | 28 | 88.9 | 46.7 | 55.6 | 84.8
| Study design: | • median age 2.6; range 0.8–10 | • median age 1.2; range 0.9–9 | | 45 | 0 | 2 | 58 | 100 | 96.7 | 95.7 | 100
| • case-control | • 21 males; 22 females | • 32 males; 28 females
| Ethnicity:
| • n/a
| Population Type:
| • n/a
| Reference test:
| • Biopsy Watson capsule
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| • Biopsies confirmed at diagnosis, on GFD, and rechallenge (severity grade-not reported)
| Checked IgA def.
| • n/r
| Studied tests
| IgA-AGA
| IgG-AGA
| IgA-EMA
| Methodology:
| • ELISA; IF likely ME
| Cut-off:
| • AGA mean +2 SD
Carroccio 2002 Italy | Publication type: | Celiac Group 1 | Group 1: | CD vs CO: EMA | 24 | 0 | 0 | 183 | 100 | 100 | 100 | 100
| • journal | • 24 consecutive pts with untreated biopsy proven CD | • 183 consecutive pts with biopsy proven non-CD disorders: IBS (n=70), esophagatis (n=45), peptic ulcers (n=41), Crohn's disease (n=15), Food intolerance (10), chronic liver disease (n=6), gastric cancer (n=2), right colon cancer (n=2), collagenous colitis (n=1), intestinal bacterial overgrowth syndrome (n=1), psoriasis (n=1) | CD vs CO: anti-GP-tTG IgA | 24 | 0 | 15 | 168 | 100 | 92 | 60 | 100
| Study design: | • age (y): median 30, range 18–80 | • age (y): median 46, range 17–84 | CD vs CO: anti-h-tTG IgA | 24 | 0 | 6 | 177 | 100 | 97 | 80 | 100
| • cohort | • % F: 58 | • % F: 51
| Ethnicity:
| • n/a
| Population Type:
| • n/a
| Reference test:
| gastroduodenoscopy and biopsy
| First test:
| • simultaneously
| Controls biopsied:
| • yes
| Biopsy criteria:
| • Ferguson and Murray; partial or total VA
| Checked IgA def.
| yes (none of CD pts showed IgA deficiency
| Studied tests
| EMA-IgA; anti-GP-tTG IgA (GP used); anti-h-tTG IgA (HR)
| Methodology:
| for EMA - IF ME; for tTG-ELISA
| Cut-off:
| anti-h-tTG IgA-results were expressed as a % of the positive control serum. Normal values were taken as <7%, which represented a value >2 SD above the mean of 850 healthy individuals; anti-gp-tTG IgA-values >95th percentile of a control group were considered positive;
Cataldo, 2000 Italy | Publication type: | Celiac Group 1 | Group 1: | Celiac 1 vs control 1 | 20 | 0 | 0 | 10 | 100 | 100 | 100 | 100
| • journal | • 20 untreated CD (biopsy proven) with IgAD | • 10 healthy IgAD controls on GD (healthy controls (not biopsied - not used) | | 0 | 20 | 0 | 10 | 0 | 100 | 0 | 33.3
| Study design: | • age/gender: n/a | • age: n/a | | 20 | 0 | 2 | 8 | 100 | 80 | 90.1 | 100
| • case-control | Celiac Group 2 | • gender: adults and children | | 0 | 20 | 0 | 10 | 0 | 100 | 0 | 33.3
| Ethnicity: | • 11 untreated CD without IgAD | Group 2 | | 20 | 0 | 0 | 10 | 100 | 100 | 100 | 100
| • n/a | • age/gender: n/a | • 25 healthy controls on a GD, first degree relatives of CD pts, adult or paediatric pts with GI diseases i.e. mild protein intolerance, pstenteritis syndrome, Crohn's disease, ulcerative colitis, or giardiasis | | 0 | 20 | 0 | 10 | 0 | 100 | 0 | 33.3
| Population Type: | | • age/gender: n/a
| • IgA deficient adults and children
| Reference test:
| • n/r
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| Original & revised criteria?
| Checked IgA def.
| • Yes
| Studied tests
| IgG-EMA
| IgA-EMA
| IgG-tTG
| IgA-tTG
| IgG-AGA
| IgA-AGA
| Methodology:
| • IgG-EMA, ME; IgG-tTG, human serum albumin
| Cut-off:
| • n/a
Chan, 2001 Canada | Publication type: | Celiac Group 1 | Group 1: | celiac 1 vs control 1 | 8 | 1 | 2 | 64 | 89 | 97 | 80 | 98
| • journal | • 9 untreated CD (biopsy + from a group of 77 children | • 62 disease controls with negative biopsy with abdominal pain, diarrhea, failure to thrive/short stature, family history of CD, Crohn's disease, vomiting, abdominal distension, ulcerative colitis, autoimmune thyroiditis/short stature, trisomy, (from a total of 77) | | 8 | 1 | 4 | 62 | 89 | 94 | 67 | 98
| Study design: | • age: 2 mos -16 y | • age 2 mos to 16 y
| • case-control | Celiac Group 2 | Group 2
| Ethnicity: | • 12 suspected CD with DM from a group of 16 DMs | • 2 DM from a group of 16 DMs
| • n/a | • age: 3–18Y
| Population Type: | Celiac Group 3
| • suspected CD | • 2 IgAD pts, one biopsy positive, (excluded in the analysis)
| Reference test:
| • Carey capsule or 4 to 6 duodenal biopsies at endoscopy
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| Villous atrophy, crypt hyperplasia, increase lymphocytes
| Checked IgA def.
| • Yes
| Studied tests
| IgA-EMA; IgA-tTG
| Methodology:
| • EMA-ME; IgA tTG ELISA GP liver
| Cut-off:
| • EMA:≥1:10; tTG: >20
Chartrand 1997 Canada | Publication type: | Celiac Group 1 | Group 1: | Celiac 1 vs Control | 24 | 6 | 12 | 134 | 80 | 92 | 67 | 96
| • journal | • 30 of 176 children suspected of CD | • 146 with suspected CD - biopsy excluded | | 25 | 5 | 31 | 115 | 83 | 79 | 45 | 96
| Study design: | • mean age: 5.2; range 0.5–18; | • mean age: n/r | | 28 | 2 | 42 | 104 | 93 | 71 | 43 | 98
| • cohort | • % F: n/r | • % F: n/r
| Ethnicity:
| • n/a
| Population Type:
| • suspected CD
| Reference test:
| • Biopsy - endoscopic
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| ESPGAN - with flat mucosal biopsy
| Checked IgA def.
| • yes - 2 of false negatives were IgA def
| Studied tests
| IgA-AGA
| IgG-AGA
| IgG or IgA
| Methodology:
| • ELISA
| Cut-off:
| • 0.25 for IgA, 0.3 for IgG (optical density)
Chirdo 1999 Argentina | Publication type: | Celiac Group 1 | Group 1: | Celiac 1 vs Control | 24 | 4 | 6 | 25 | 85.7 | 80.6 | 80 | 86
| • journal | • 28 pts, biopsy proven untreated | • 31 disease controls; chronic diarrhea, short stature, abdominal distension | | 23 | 5 | 8 | 23 | 82.1 | 74.2 | 74 | 82
| Study design: | • mean age: 7 y; range 13 mos-14 y | • mean age: 5.4 y, 2–12 y | | 25 | 3 | 5 | 26 | 89.3 | 83.9 | 83 | 90
| • cohort | • % F: 15 (54%) | • 13 F, 18 M | | 21 | 7 | 4 | 27 | 75 | 87.1 | 84 | 80
| Ethnicity: | | | | 18 | 10 | 3 | 28 | 64.3 | 90.3 | 86 | 74
| • n/a | | | | 24 | 4 | 1 | 30 | 85.7 | 96.8 | 96 | 88
| Population Type:
| • suspected CD
| Reference test:
| • n/r
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| Total or subtotal VA
| Checked IgA def.
| • n/a
| Studied tests
| IgG commercial gliadin; IgG ethanolic extract; IgG ω-gliadins ; IgA commercial gliadin; IgA ethanolic extract; IgA IgG ω-Gliadins
| Methodology:
| • ELISA
| Cut-off:
| • n/r
Chirdo 2000 Argentina | Publication type: | Celiac Group 1 | Group 1: | Celiac 1 vs control 3 | 94 | 11 | 5 | 41 | 89.5 | 89.1 | 94.9 | 78.8
| • journal | • 105 untreated CD pts (biopsy proven) | • 45 healthy controls | | 100 | 5 | 9 | 37 | 95.2 | 80.4 | 91.7 | 88.1
| Study design: | • mean age: 6.5 y; range 16 mos-15 y | • mean age 8.5 y; range 3–14 y | | 97 | 8 | 0 | 46 | 92.4 | 100 | 100 | 85.2
| • case control | • % F: n/r | Group 2:
| Ethnicity: | | • 36 healthy blood donors
| • n/a | | • mean age 36, range 22–45 y
| Population Type: | | Group 3:
| • n/a | | • 46 biopsy negative disease control; presenting with short stature, chronic diarrhoea, parasitic infection
| Reference test: | | • mean age 5.2 y; range 1.5–14 y this group used for analysis
| Intestinal biopsy | | Group 4:
| First test: | | • 27 disease controls with Crohn's disease, ulcerative colitis, or Helicobacter pylori infection
| • biopsy
| Controls biopsied:
| • only group 3
| Biopsy criteria:
| ESPGAN
| Checked IgA def.
| • Yes
| Studied tests
| IgA w-AGA; IgG w-AGA; not a commercial kit (not used) IgA-EMA (used)
| Methodology:
| • IgA-EMA-ME IF
| Cut-off:
| • cut-off value for each antigen by using the same set of samples. Five control samples used as reference to normalize the day-to-day variation
Dahele 2001 Scotland | Publication type: | Celiac Group 1 | Group 1: | Celiac 1 vs Control 1 | 34 | 19 | 10 | 55 | 64 | 85 | 77 | 74
| • journal | • 53 untreated CD pts (biopsy proven) | • 65 controls pts | | 44 | 8 | 14 | 51 | 83 | 78 | 76 | 86
| Study design: | • median age 51 y; range 22–77 y | • median age: 45 y; range 17–90 y | | 40 | 13 | 0 | 65 | 75 | 100 | 100 | 83
| • case control | • 39 F; 14 M | • 46 F; 19 M | | 35; | 18 | 3 | 62 | 66 | 92 | 92 | 78
| Ethnicity:
| • n/a
| Population Type:
| • suspected CD
| Reference test:
| duodenal biopsy
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| Included partial VA or greater
| Checked IgA def.
| • Yes
| Studied tests
| IgA AGA; IgG AGA; IgA EMA; IgA tTG
| Methodology:
| • IgA AGA, ELISA; IgG-AGA, ELISA; IgA-EMA, HU; IgA-tTG ELISA GP liver
| Cut-off:
| • for IgA & IgG AGA: ≥30 unit/mL & ≥45 units/mL, respectively
Dahele 2001 Scotland | Publication type: | Celiac Group 1 | Group 1: | Celiac 1 vs Control 1 | 69 | 45 | 9 | 56 | 61 | 86 | 88.5 | 42.7
NB: update of Dahele et al., Dig Dis Sci; 2001;46:214 | • journal | • 116 untreated CD pts (biopsy proven) | • 65 control pts (suspected CD pts with normal biopsy) | | 99 | 15 | 0 | 65 | 87 | 100 | 100 | 81.3
| Study design: | • median age: 47 y; range 15–78 y | • median age 45 y; range 16–90 y | | 92 | 22 | 2 | 63 | 81 | 97 | 97.9 | 74.1
| • case control | • 74 F; 42 M | • 45 F; 20 M
| Ethnicity:
| • n/a
| Population Type:
| • suspected CD
| Reference test:
| duodenal biopsy
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| Included 6 with IEL, rest partial VA or greater
| Checked IgA def.
| • yes - 2 IgA deficient excluded (114/116 CD used)
| Studied tests
| IgA AGA; IgA AEM; IgA tTG
| Methodology:
| • IgA-AGA, ELISA; IgG-AGA, ELISA; IgA-EMA, HU; IgA tTG ELISA GP liver
| Cut-off:
| • for IgA & IgG AGA: ≥30 unit/mL & ≥45 units/mL, respectively
Di Leo 1999 Italy | Publication type: | Celiac Group 1 | Group 1: | group 1 vs control, EIA IgA | 50 | 5 | 1 | 64 | 90.9 | 98.5
| • journal | • 45 untreated pts (biopsy proven untreated) | • 67 healthy controls | group 1 vs control, EIA IgG | 53 | 2 | 20 | 45 | 96.4 | 69.2
| Study design: | • mean age: 6.11 y; range 9 mos-17 y | • mean age: 8 y. 9 mos; range 1 y. 4 mos-16 y. 9 mos | group 1 vs control, DIG-ELISA IgA | 50 | 5 | 2 | 63 | 90.9 | 96.9
| • case control | • 32 F, 13 M | • 43 F, 24 M | group 1 vs control, DIS-ELISA IgA | 48 | 7 | 9 | 56 | 87.3 | 86.2
| Ethnicity: | Celiac Group 2 | | group 1 vs control, ARA | 48 | 6 | 18 | 47 | 88.9 | 72.3
| • n/a | • 18 GDF pts (celiac on GFD) | | group 1 vs control, Human JAB | 55 | 0 | 18 | 47 | 100 | 72.3
| Population Type: | • mean age: 13.2 y; range 3 y 8 mos-16 y 6 mos | | group 1 vs control, RAT JAB | 55 | 0 | 11 | 54 | 100 | 83.1
| • n/a | • 13 F, 5 M | | group 1 vs control, EMA | 54 | 1 | 0 | 65 | 98.2 | 100
| Reference test: | | | group 3 vs control, EIA IgA | 20 | 1 | 1 | 64 | 95.5 | 98.5
| biopsy | | | group 3 vs control, EIA IgG | 19 | 2 | 20 | 45 | 90.5 | 69.2
| First test: | | | group 3 vs control, DIG-ELISA IgA | 17 | 4 | 2 | 63 | 80.9 | 96.9
| • biopsy | | | group 3 vs control, DIS-ELISA IgA | 15 | 5 | 9 | 56 | 75 | 86.1
| Controls biopsied: | | | group 3 vs control, ARA | 18 | 3 | 18 | 47 | 85.7 | 72.3
| • yes | | | group 3 vs control, Human JAB | 21 | 0 | 18 | 47 | 100 | 72.3
| Biopsy criteria: | | | group 3 vs control, RAT JAB | 18 | 3 | 11 | 54 | 85.7 | 83
| ESPGAN | | | group 3 vs control, EMA | 19 | 2 | 0 | 65 | 90.5 | 100
| Checked IgA def.
| • yes
| Studied tests
| EIA-IgA; EIA-IgG; DIG-ELISA IgA; DIG-ELISA IgG; ARA; human JAB-IgA; Rat JAB; EMA-IgA
| Methodology:
| • for EIA-IgA and IgG-ELISA; for ARA-IF; for EMA, JAB-immunohistochemical method
| • Cut-off
| EIA IgA and IgG: 35 AU (arbitrary units) for children <5 y; and 20 AU for children >5 y; DIG-ELISA: IgA values >13 mm and IgG values >16 mm were considered positive in children <5 y; IgA values <11 mm and IgG values >14 mm - in children >5 y
Dickey 2001 Northern Ireland | Publication type: | Celiac Group 1 | Group 1: | Celiac 1 vs Control 1 | 55 | 18 | 1 | 57 | 75.3 | 98.3 | 98.2 | 76.0
| • journal | • 73 untreated biopsy-proven CD pts | 58 disease controls; diarrhea, anaemia, family history of celiac and others | | 68 | 5 | 2 | 56 | 93.3 | 96.6 | 97.1 | 91.8
| Study design: | • age 13–72 y
| • case control | • 45 F, 28 M
| Ethnicity:
| • n/a
| Population Type:
| • n/a
| Reference test:
| • n/a
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| VA
| Checked IgA def.
| • no
| Studied tests
| EMA (excluded); tTGA; EMA and/or tTGA
| Methodology:
| • EMA=ME; tTGa, ELISA GP liver
| Cut-off:
| >30 as positive
Faith-Magnusson 1994 Sweden | Publication type: | Celiac Group 1 | Group 1: | Celiac 1 vs Control 1 | n/r | n/r | n/r | n/r | 98.1 | 27.8
| • journal | • 116 pts; biopsied twice; median time on GFD pre 2nd biopsy 13 mos (10–24 mos) | • 199 disease controls; poor weight gain; diarrhea; stature | | | | | | 95.2 | 39.5
| Study design: | • age @ 1st biopsy median 13 mos, range 0.7–16.7 y, age @ 2nd biopsy 29 mos range 1.6–17.8 y | • median age 22 mos range 0.7–16.8 y | | | | | | 91.4 | 70.5
| • cohort | • 73 F; 43 M | • 105 F; 94 M | | | | | | 88.6 | 92.3
| Ethnicity: | | | | | | | | 93.3 | 64.6
| • n/a | | | | | | | | 88.7 | 75.8
| Population Type: | | | | | | | | 88.7 | 82.3
| • suspected CD | | | | | | | | 88.7 | 93.5
| Reference test:
| • Watson capsule or Stortz
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| ESPGAN+ Alexander grading IV, grade III to IV callenge
| Checked IgA def.
| • no
| Studied tests
| DIG - ELISA combined IgA & IgG; ELISA combined IgA & IgG
| Methodology:
| • ELISA; DIG-ELISA
| Cut-off:
| DIG ELISA (mm) combined IgA+IgG ≥ 6 and /or; ≥10; ≥12; ≥14; ≥16; ELISA (mm) for combined IgA+IgG ≥0.25; and; ≥0.8; ≥0.9; ≥1.0; ≥1.1
Gilbert 2000 Canada | Publication type: | Celiac Group 1 | Group 1: | Celiac 1 vs Control | 21 | 0 | 0 | 42 | 100 | 100
| • journal | • 21 CD adults | • biopsied disease controls with CD excluded | | 20 | 1 | 0 | 42 | 95.2 | 100
| Study design: | • age: n/r | • age: n/r
| • case control | • % F: n/r | • % F: n/r
| Ethnicity:
| • n/a
| Population Type:
| • n/r
| Reference test:
| • biopsy
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| mild, moderate, severe VA
| Checked IgA def.
| • n/r
| Studied tests
| IgA-EMA; IgA-tTG
| Methodology:
| •EMA-HU
| •tTG- HR
| Cut-off:
| EMA:≥1:5; tTG: >400u
Gonczi 1991 Australia | Publication type: | Celiac Group 1 | Group 1: | celiac 1 vs control 1-IgA-AGA | 19 | 1 | 6 | 73 | 95 | 92.4 | 76 | 98.6
| • journal | • 20 children untreated biopsy-proven CD | • 79 children biopsy-negative controls w sx | celiac 1 vs control 1-IgG - AGA | 20 | 0 | 6 | 73 | 100 | 92.4 | 76.9 | 100
| Study design: | • age: n/r | • age: n/r | celiac 1 vs control 1- IgA+IgG | 20 | 0 | 1 | 78 | 100 | 98.7 | 95.2 | 98.7
| • cohort | • % F: n/r | • % F: n/r | celiac 2 vs control 2-IgA-AGA | 23 | 2 | 4 | 30 | 92 | 88.2 | 85.2 | 93.8
| Ethnicity: | Celiac Group 2 | Group 2: | celiac 2 vs control 2-IgG - AGA | 25 | 0 | 11 | 23 | 100 | 69.7 | 69.4 | 100
| • n/r | • 25 untreated adults biopsy-proven CD | • 34 adult disease controls | celiac 2 vs control 2- IgA+IgG | 25 | 0 | 1 | 33 | 100; | 97.1 | 96.2 | 100
| Population Type: | • age: n/r | • age: n/r
| • suspected celiac; single institution 1977-1983; mean age 3.97 (range 1 mos-16 y) | • % F: n/r | • % F: n/r
| Reference test:
| • biopsy technique not reported (likely capsule)
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| ESPGAN no details on biopsy findings
| Checked IgA def.
| • yes - 1 CD child
| Studied tests
| IgA AGA; IgG-AGA
| Methodology:
| •ELISA mean + 2 SD; IgA 25 AU; IgG 46
| Cut-off:
| 20.2%
Hallstrom 1989 Findland | Publication type: | Celiac Group 1 | Group 1: | celiac 1 vs control 1 | 29 | 3 | 0 | 24 | 90.6 | 100 | 100 | 88.9
| • journal | • 32 untreated adult CD pts | • 24 non-CD children by biopsy, with various abdominal symptoms | celiac 2 vs control 1 | 18 | 0 | 0 | 24 | 100 | 100 | 100 | 100
| Study design: | • mean age 36 y; range 18–63 y) | • mean age 7.5 y; range 1–15
| • case control | • % F: n/r | • % F: n/r
| Ethnicity: | Celiac Group 2
| • n/r | • 18 children with untreated CD
| Population Type: | • mean age 1; range 2–16
| • n/a | • % F: n/r
| Reference test:
| • biopsy
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| Flat mucosa
| Checked IgA def.
| • yes
| Studied tests
| IgA - EMA
| Methodology:
| •EMA-ME
| Cut-off:
| n/r
Hansson 2000 Sweden | Publication type: | Celiac Group 1 | Group 1: | Celiac 1 vs Control 1 | 21 | 1 | 0 | 23 | 95.5 | 100 | 100 | 95.8
| • journal | • 22 untreated pts (biopsy proven CD) | • 23 disease controls (note: no biopsy for the 5/23 control group); GI symptoms; inflammatory bowel disease; cow's milk protein intolerance; food intolerance; miscellaneous GI disorders 17 confirmed biopsy negatives | | 21 | 1 | 6 | 17 | 95.5 | 73.9 | 77.8 | 94.4
| Study design: | • median age 3 y; range 1–16 y | • median age: 6 y, range 1–16 y | | 18 | 4 | 4 | 19 | 81.8 | 82.9 | 81.8 | 82.6
| • case control | • 14 F, 8 M | • 9 F, 13 M | | 21 | 1 | 1 | 22 | 95.5 | 95.7 | 95.5 | 95.7
| Ethnicity: | | | | 22 | 0 | 0 | 23 | 100 | 100 | 100 | 100
| • n/r | | | | 20 | 2 | 1 | 22 | 90.9 | 95.7 | 95.2 | 91.7
| Population Type:
| • n/a
| Reference test:
| • n/r
| First test:
| • serology test
| Controls biopsied:
| • no
| Biopsy criteria:
| ESPGAN
| Checked IgA def.
| • no
| Studied tests
| IgA EMA; IgA serum; IgG AGA; IgA tTG; human erythrocyte tTG; tTG GP liver
| Methodology:
| •IgA-EMA-ME; tTG, ELISA (human)
| Cut-off:
| n/r
Iltanen 1999 Finland | Publication type: | Celiac Group 1 | Group 1: | celiac 1 vs control 1 | 20 | 0 | 13 | 44 | 100 | 77.1 | 60.1 | 100
| • journal | • 23 CD children out of 78 evaluated for suspected CD | • 57 biopsy negative children who were suspected of CD
| Study design: | • median age: overall group 6.5; range 0.5–15.8 | • age: n/r
| • cohort | • % F: n/r | • % F: n/r
| Ethnicity:
| • n/r
| Population Type:
| • 78 children with suspected CD
| Reference test:
| • biopsy
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| ESPGAN - CD confirmed at follow-up
| Checked IgA def.
| • n/r
| Studied tests
| IgA - EMA
| Methodology:
| • HU - IF
| Cut-off:
| >=1:5
Kaukinen, 2000 Finland | Publication type: | Celiac Group 1 | Group 1: | celiac 1 vs control 1 | 7 | 1 | 0 | 84 | 88.9 | 100 | 100 | 98.9
| • journal | • 93 pts with self-reported suffering from GI symptoms upon gluten ingestion | • 84 of 93 with negative biopsy | | 8 | 0 | 0 | 84 | 100 | 100 | 100 | 100
| Study design: | • mean age: 39 y; range 17–73 y; 9 CD pts | • age: n/r | | | | | | 83 | 45
| • cohort | • % F: 70; 23 M | • % F: n/r | | | | | | 17 | 86
| Ethnicity:
| • n/r
| Population Type:
| • pts suspected of CD with self reported symptoms upon gluten ingestion
| Reference test:
| • biopsy
| First test:
| • simultaneous
| Controls biopsied:
| • yes
| Biopsy criteria:
| Villous height to crypt ration <2.0; IEL and HLA also tested
| Checked IgA def.
| • n/r
| Studied tests
| IgA EMA; IgA htTg; IgA AGA; IgG AGA
| Methodology:
| • IF-EMA-HU; Human recombinant TTG ELISA (from Enova Diagnostics web site); AGA ELISA
| Cut-off:
| ≥1:5; ≥20 U; IgA-AGA ≥0.2 EU/mL; IgG-AGA ≥10 EU/mL
Kolho, 1997 Finland | Publication type: | Celiac Group 1 | Group 1: | CD untreated and on gluten challenge (group 1) vs control groups 1–4 (combined in the study) | 50 | 3 | 0 | 114 | 95 | 100 | 100 | 97
| • journal | • 53 pts newly diagnosed CD (biopsy proven) | • 48 pts children/adolescents GI complaints; disturbed growth or elevated AGA titres (normal biopsy) | CD gluten challenged vs control EMA | 50 | 3 | 0 | 114 | 95 | 100 | 100 | 97
| Study design: | • mean age: 6.46 y (range 0.77–19.7 y) | • median age 5.39 y (age range 0.63–13.3 y) | | 13 | 0 | 0 | 13 | 100 | 100 | 100 | 100
| • case control | • gender: n/r | • % F: n/r | | 13 | 0 | 0 | 13 | 100 | 100 | 100 | 100
| Ethnicity: | Celiac Group 2 | Group 2:
| • n/r | • 22 pts with CD in remission (CD on GFD) | • 20 pts with cow's milk sensitivity enteropathy n/r
| Population Type: | • age (range 0.77–19.7 y) | Group 3:
| • suspected CD; or reason to exclude CD | • gender: n/r | • 23 pts with inflammatory bowel disease n/r
| Reference test: | Celiac Group 3 | Group 4:
| • Biopsy either ingestible capsule technique or endoscopically | • 13 CD pts gluten challenge | • 23 pts with diabetes mellitus n/r
| First test: | • age range: 0.77–19.7 y
| • biopsy | • gender: n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| revised ESPGAN
| Checked IgA def.
| • yes – in pts with neg serology
| Studied tests
| EMA (HU); EMA (ME)
| Methodology:
| • EMA-ME
| • EMA-HU
| Cut-off:
| cut off level was 20% for class IgA and IgG antibodies
Kumar, 1989 USA, Israel | Publication type: | Celiac Group 1 | Group 1: | CD untreated and suspected untreated and 8 biopsy + family members vs Control 1 (106–8), 2, 3 | 73 | 3 | 11 | 376 | 96 | 89 | 87 | 96.7
| • journal | • 38 children (biopsy proven); untreated CD | • 106 asymptomatic family members
| Study design: | • age: n/r | • age & gender: n/r
| • relevant clinical population and control cases | • gender n/r | Group 2:
| Ethnicity: | Celiac Group 2 | • 52 children with chronic diarrhea; 30 ulcerative colitis; 65 Crohn's disease; 21 liver disease; 34 recurrent abdominal pain
| • n/r | • 37 pts; GFD treated. | • age & gender: n/r
| Population Type: | • age: n/r | Group 3:
| • suspected CD; asymptomatic family members | • gender: n/r | • 87 healthy subjects
| Reference test: | Celiac Group 3 | • age & gender: n/r
| • Crosby-Kugler capsule | • 30 suspected CD; on gluten diet
| First test: | Celiac Group 4
| • biopsy | • 30 suspected cd on GFD
| Controls biopsied:
| • yes
| Biopsy criteria:
| ESPGAN + Townley
| Checked IgA def.
| • no
| Studied tests
| IgA-EMA
| Methodology:
| • IgA EMA, IF studies; ME
| Cut-off:
| n/r
Ladinser, 1994 Italy | Publication type: | Celiac Group 1 | Group 1: | 20 active untreated cases vs control group; IgA-EMA (HU) | 20 | 0 | 0 | 75 | 100 | 100 | 100 | 100
| • journal | • 20 biopsy-proven CD pts | • 35 pts (CD on GFD) with positive AGA serum samples no histological abnormalities | 20 active untreated cases vs control group IgA-EMA (ME) | 18 | 2 | 0 | 75 | 90 | 100 | 100 | 98
| Study design: | • mean age: 35 y (range 5–68) | • Mean age: 40 y (range 3–65)
| • case control | • % F: 67%; 20 on gluten-containing diet | • % F: 57%
| Ethnicity: | Celiac Group 2 | Group 2:
| • n/r | • 10 pts GFD (subset of original 30) | • 40 non-celiac pts without GI disorder with AGA below average range (IgA<5 and IgG <15)
| Population Type: | • age: n/r | • mean age: 37 y (range 5–65)
| • n/r | • gender: n/r | • % F: 50%
| Reference test:
| • endoscopic biopsy; IgA EMA
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| revised ESPGAN
| Checked IgA def.
| • IgA deficiency excluded by serum testing
| Studied tests
| IgA EMA
| Methodology:
| • IgA-EMA, IF studies HU smooth muscle; IgA-EMA, IF studies ME
| Cut-off:
| n/r
Lerner, 1994 USA, Israel | Publication type: | Celiac Group 1 | Group 1: | CD1 vs CO IgA-AGA | | | | | 52 | 94 | 87 | 74
NB: duplicate of Pacht et al., Isr J Med Sci 1995;31:218 (used data from Lerner et al, 1994 since more complete and larger control group) | • journal | • 34 biopsy proven CD | • 9 pts abnormal biopsy pathological control grade II-IV atrophy; (3) Giardia lamblia (3) protracted diarrhea (1) Crohn's (1) HSP (1) intestinal lymphangectasis (1) hypogammaglobulinaemia | CD1 vs CO IgG-AGA | | | | | 88 | 92 | 88 | 92
| Study design: | • mean age: 9.6 (range 1.7–17 y) | • mean age 9.3 y (range 2–16 y) | CD1 vs CO IgA-ARA-r | | | | | 65 | 100 | 100 | 77
| • case control | • male:female: 0.6:1.0 | • male:female 1.2:1 | CD1vs CO IgA-ARA-m | | | | | 53 | 100 | 100 | 71
| Ethnicity: | | Group 2: | CD1 vs CO IgA-EMA; | | | | | 97 | 98 | 97 | 98
| n/r | | • 32 pts with normal intestinal morphology (GCD)
| Population Type: | | • mean age: 8.4 y (range 1–16 y)
| n/r | | • male:female 0.9:1
| Reference test:
| • Crosby capsule
| First test:
| • simultaneous Biopsy & serology
| Controls biopsied:
| • yes
| Biopsy criteria:
| criteria of Townley modified by Ingkaran
| Checked IgA def.
| • no
| Studied tests
| IgA -AGA; IgG-AGA; IgA-ARA (rat kidney); IgA-ARA (mouse kidney); IgA-EMA ME
| Methodology:
| AGA=ELISA; ARA=IF rat & mouse kidney; EMA=IF ME
| Cut-off:
| ELISA 2 SD above the mean of normal value considered positive
Lindberg, 1985 Sweden | Publication type: | Celiac Group 1 | Group 1: | Author reports groups as:
NB: duplicate Jardas et al., Pol J Immunol 1994;19:49 | • journal | • 25 pts untreated CD; 29 pts probable CD | • 121 pts with other GI disorders i.e., unspecified diarrhea, cow's milk protein intolerance, multiple food allergies, post infectious diarrhea, diarrhea caused by Yersinia enterocolitica | CD severely damaged intestinal mucosa vs control IgA AGA | | | | | 88 | 88
| Study design: | • mean age: 12 months (range 7–132 mos) | • mean age 14 mos (7–130 mos) | CD severely damaged intestinal mucosa vs control IgG AGA | | | | | 93 | 89
| • cohort | • gender: n/r | • gender: n/r | CD severely damaged intestinal mucosa vs control IgA/IgG AGA | | | | | 97 | 83
| Ethnicity: | • 58 pts in total used (with severely damaged mucosa) | Group 2:
| • n/r | Celiac Group 2 | • 23 pts short stature no GI symptoms
| Population Type: | • 32 pts CD treated GFD (2nd biopsy) | • mean age: 48 mos (range 12–180 mos)
| • suspected malabsorption | • mean age: 30 mos (range 18–168 mos) | • gender: n/r
| Reference test: | • gender: n/r | NB: the study combined control 1 and control 2 (132 pts)
| • biopsy duodenojejunal flexure Watson pediatric capsule EMA | Celiac Group 3
| First test: | • 37pts confirmed CD challenged period with gluten
| • biopsy & serology simultaneous (sera collected ± 2 weeks of biopsy) | • mean age: 36 mos (range 16–192 mos)
| Controls biopsied: | • gender: n/r
| • yes
| Biopsy criteria:
| ESPGAN and Alexander grades; reported sensitivity and specificity for pts with severely damaged mucosa
| Checked IgA def.
| • yes
| Studied tests
| IgA-AGA; IgG-AGA; combined IgA/IgG
| Methodology:
| • DIG-ELISA
| Cut-off:
| 11 mm IgA; 14mm IgG combined
Lindquist, 1994 Sweden | Publication type: | Celiac Group 1 | Group 1: | Celiac 1 & 2 vs control 1 EMA | 51 | 1 | 3 | 38 | 98.1 | 92.7 | 94.4 | 97.5
| • journal | • 42 confirmed CD pts (meets ESPGAN criteria) | • 25 pts with other pathology (CD excluded) | Celiac 1 & 2 vs control 1 IgA | 45 | 7 | 3 | 39 | 86.5 | 92.7 | 93.7 | 85
| Study design: | • mean age: 2.7 y (range 5 mos-14.4 y) | • mean age: 2.7 y (range 5 mos–14.4 y)
| • cohort | • % F: 48 | • % F: 48
| Ethnicity: | Celiac Group 2
| • n/r | • 10 suspected CD pts with characteristic biopsy but repeat biopsy on GFD was pending
| Population Type: | • mean age: 2.7 y (range 5 mos–14.4 y)
| • suspected CD | • % F: 48
| Reference test:
| • paediatric Watson capsule
| First test:
| • Simultaneous biopsy & serology
| Controls biopsied:
| • yes
| Biopsy criteria:
| ESPGAN; subtotal or partial VA
| Checked IgA def.
| • yes
| Studied tests
| IgA-EMA
| IgA-AGA
| Methodology:
| IgA-EMA, indirect IF & ME; IgA-AGA, DIG-ELISA
| Cut-off:
| IgA-AGA >11mm regarded as positive
Maki, 1991 Finland | Publication type: | Celiac Group 1 | Group 1: | Celiac 1 & 2 vs control 1 EMA | 51 | 1 | 3 | 38 | 98.1 | 92.7 | 94.4 | 97.5
| • journal | • 42 confirmed CD pts (meets ESPGAN criteria) | • 25 pts with other pathology (CD excluded) | Celiac 1 & 2 vs control 1 IgA | 45 | 7 | 3 | 39 | 86.5 | 92.7 | 93.7 | 85
| Study design: | • mean age: 2.7 y (range 5 mos–14.4 y) | • mean age: 2.7 y (range 5 mos–14.4 y)
| • cohort | • % F: 48 | • % F: 48
| Ethnicity: | Celiac Group 2
| • n/r | • 10 suspected CD with characteristic biopsy but repeat biopsy on GFD was pending
| Population Type: | • mean age: 2.7 y (range 5 mos–14.4 y)
| • suspected celiac | • % F: 48
| Reference test:
| • paediatric Watson capsule
| First test:
| • Simultaneous Biopsy & serology
| Controls biopsied:
| • yes
| Biopsy criteria:
| ESPGAN; subtotal or partial VA
| Checked IgA def.
| • yes
| Studied tests
| IgA-EMA
| IgA-AGA
| Methodology:
| IgA-EMA, indirect IF & ME; IgA-AGA, DIG-ELISA
| Cut-off:
| IgA-AGA > 11mm regarded as positive
McMillan, 1991 Ireland | Publication type: | Celiac Group 1 | Group 1: | Celiac group 1 vs control group 2 | 21 | 7 | 4 | 57 | 75 | 93.4 | 84 | 89
| • journal | • 23 biopsy proven CD + 5 probable CD = 28 pts | • 7 pts 2 did not respond to GFD 4 had ulcerative colitis (1 of those pts had partial VA); 1 had IBS | | 21 | 7 | 0 | 61 | 75 | 100 | 100 | 90
| Study design: | • Adults age (y): 16–89 | • mean age: n/r | | 16 | 12 | 9 | 52 | 57 | 85 | 64 | 81
| • cohort | • % F: n/r | • % F: n/r | | 28 | 0 | 0 | 61 | 100 | 100 | 100 | 100
| Ethnicity: | | Group 2: | | 11 | 17 | 1 | 60 | 39 | 98.3 | 92 | 78
| • n/r | | • 61 normal results of jejunal biopsies | | 25 | 3 | 0 | 61 | 89.2 | 100 | 100 | 95.3
| Population Type: | | | | 15 | 13 | 0 | 61 | 54 | 92 | 75 | 81
| • suspected celiac | | | | 21 | 7 | 0 | 61 | 75 | 100 | 100 | 90
| Reference test:
| • Crosby capsule “muzzle loaded”
| First test:
| • simultaneous Biopsy & serology
| Controls biopsied:
| • yes
| Biopsy criteria:
| revised ESPGAN
| Checked IgA def.
| • yes
| Studied tests
| IgG-AGA; IgA-AGA; IgG-AGA; IgA-AGA; IgG-EMA; IgA-EMA; IgA jejunum; IgG jejunum
| Methodology:
| • AGA by indirect IF; AGA by ELISA; EMA by IF, ME; jejunum, IF with sections of black hooded rat jejunum as antigen
| Cut-off:
| titre of one in 20 or greater were considered positive
Meini, 1996 Italy | Publication type: | Celiac Group 1 | Group 1: | celiac 1 vs control 1 | 0 | 5 | 0 | 55 | 0 | 100 | - | 91.7
| • journal | • 5 pts; untreated; IgA-deficient | • 60 biopsy-negative IgA-deficient | | 5 | 0 | 11 | 44 | 100 | 80 | 31.2 | 100
| Study design: | • mean age: 8.8 y; range 7–11 y
| • cohort | • % F: 80
| Ethnicity:
| • n/r
| Population Type:
| • 65/85 IgA-def pts seen in single immunology clinic 1989-93 (76.5%)
| Reference test:
| • Watson capsule
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| partial VA or total VA
| Checked IgA def.
| • yes
| Studied tests
| IgA-AGA; IgG-AGA
| Methodology:
| ELISA
| Cut-off:
| 25 AU/dL
Picarelli, 2000 Italy | Publication type: | Celiac Group 1 | Group 1: | celiac 1 vs control 1 and EMA | 18 | 0 | 0 | 135 | 100 | 100 | 100 | 100
| • journal | • 30 EMA neg suspected CD; 18 confirmed cases CD | • 60 disease control (other GI diseases) | celiac 1 vs control 3 for IgA-AGA | 4 | 14 | 4 | 8 | 22.2 | 66.7 | 50 | 36.3
| Study design: | • mean age: 10.6 y (age range 2–16 y) | • mean age: 11.3 y (age range 4–16) | IgG-AGA | 6 | 12 | 5 | 7 | 33.3 | 58.3 | 54.5 | 36.8;
| • case control | • % F: 60 | • % F: 55
| Ethnicity: | | Group 2:
| • n/r | | • 63 healthy children
| Population Type: | | • mean age 10.5 y (age range 3–16 y)
| • suspected CD | | • % F: 52 - this group not biopsied so not used
| Reference test: | | Group 3:
| • EMA; biopsy (EGD) 2 biopsies | | • 12 suspected CD pts biopsy negative
| First test:
| • EMA serology
| Controls biopsied:
| • yes
| Biopsy criteria:
| ESPGAN
| Checked IgA def.
| • yes 9 of 18 IgA deficient
| Studied tests
| IgG-EMA; IgA-AGA; IgG-AGA
| Methodology:
| EMA, indirect IF ME; AGA, in house ELISA
| Cut-off:
| 0.9 for AGA-IgA and 1.1 for AGA-IgG
Poddar, 2002 India | Publication type: | Celiac Group 1 | Group 1: | celiac 1 vs control 1 | 47 | 3 | 4 | 43 | 94 | 91.5 | 92 | 93.5
| • journal | • 50 CD children of 100 biopsied for suspected CD | • 44 biopsy-negative controls who were suspected of CD
| Study design: | • mean age: 6.3; range 2.5–12 y
| • cohort | • % F: n/r
| Ethnicity:
| • n/r
| Population Type:
| • suspected CD
| Reference test:
| • biopsy - endoscopic
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| ESPGAN (VA and unequivocal response to GFD)
| Checked IgA def.
| • n/r
| Studied tests
| IgA-AGA
| Methodology:
| ELISA
| Cut-off:
| 5U/mL
Rich, 1990 USA | Publication type: | Celiac Group 1 | Group 1: | celiac vs CO: Xylose | 14 | 1 | 24 | 21 | 93 | 47 | 36.8 | 84
| • journal | • 15 biopsy-proven CD pts out of 60 consecutive group of children suspicious of having CD | • 45 non-CD biopsies out of 60 consecutive group of children suspicious of having CD | celiac vs CO: IgG AGA | 15 | 0 | 19 | 26 | 100 | 58 | 44 | 100
| Study design: | • age: n/r | • age: n/r | celiac vs CO: IgA AGA | 8 | 7 | 3 | 42 | 53 | 93 | 72.7 | 85.7
| • cohort | • % F: n/r | • % F: n/r
| Ethnicity:
| • n/a
| Population Type:
| • n/a
| Reference test:
| pediatric suction biopsy technique under fluoroscopic control
| First test:
| • n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| n/r - state “severe” lesion
| Checked IgA def.
| • n/r
| Studied tests
| xylose; IgA-AGA; IgG-AGA
| Methodology:
| D-xylose absorption test; for AGA - ELISA
| Cut-off:
| xylose ≤25 mg/dL was considered abnormal; AGA - Ab levels >2 SD above the mean of the reference group of normal subjects were considered to be abnormal
Russo, 1999 Canada | Publication type: | Celiac Group 1 | Group 1: | celiac vs control IgG-AGA | | | | | 83.3 | 84.5 | 64.5 | 93.8
| • journal | • 24 pediatric pts with CD (biopsy proven) diagnosed by evaluating consecutive group of 95 children with suspected CD | • 71 children with biopsy proved non-CD enteropathies or normal mucosa | celiac vs control IgA-AGA; | | | | | 83.3 | 85.9 | 66.7 | 93.8
| Study design: | • age: mean 3.5 y, range 7 mos-11 y | • age: n/r | celiac vs control EMA ME | | | | | 75 | 88.7 | 69.2 | 91.3
| • cohort | • % F: 50 | • % F: n/r | celiac vs control EMA HU | | | | | 45.8 | 95.8 | 78.6 | 84
| Ethnicity: | | | parallel | | | | | 100 | 73 | 57 | 82
| • n/a | | | series | | | | | 100 | 93 | 86 | 100
| Population Type:
| • n/a
| Reference test:
| endoscopic biopsy
| First test:
| • n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| ESPGAN
| Checked IgA def.
| yes (1 pts with CD were found to be IgA deficient)
| Studied tests
| AGA-IgA; AGA-IgG; EMA ME; EMA HU
| Methodology:
| for AGA-IgA and IgG ELISA; for EMA - IF on either ME, or HU
| Cut-off:
| for AGA-gA cut-off was 0.25 EU and for AGA-IgG 0.3 EU; for EMA positive results were considered when a characteristic honeycomb pattern was observed around the smooth muscle
Salmaso, 2001 Italy | Publication type: | Celiac Group 1 | Group 1: | celiac 1 vs control 1 | 20 | 3 | 0 | 58 | 87 | 100 | 100 | 95.1
| • journal | • 23 adult untreated CD pts | 58 adult age-matched biopsy-negative controls | | 20 | 3 | 2 | 56 | 87 | 97 | 90.9 | 94.9
| Study design: | • median age: 50; range 27–96 | Group 2: | celiac 2 vs control 2 | 59 | 0 | 0 | 48 | 100 | 100 | 100 | 100
| • case control | • % F: 56.5 | 48 children age-matched biopsy-neg controls | | 56 | 3 | 0 | 48 | 95 | 100 | 100 | 94.1
| Ethnicity: | Celiac Group 2
| • n/a | • 59 children with untreated CD
| Population Type: | • median age: 8.2 y; range 2–14
| consecutive CD Dx 1996-99 | • % F: 37.3
| Reference test:
| • no info on biopsy
| First test:
| • biopsy?
| Controls biopsied:
| • yes
| Biopsy criteria:
| grades 1-1V Marsh with response to GFD
| Checked IgA def.
| yes; IgA deficients were excluded
| Studied tests
| IgA-EMA; IgA-tTG
| Methodology:
| UC EMA; GP-tTG antigen
| Cut-off:
| tTG=20 AU
Sategna-Guidetti, 1995 Italy | Publication type: | Celiac Group 1 | Group 1: | celiac vs CO EMA | 100 | 0 | 0 | 109 | 100 | 100 | 100 | 100
| • journal | • 100 untreated biopsy-proven CD pts | • 52 healthy volunteers recruiting among medical and nursing staff | celiac vs CO JAB | 100 | 0 | 0 | 109 | 100 | 100 | 100 | 100
| Study design: | • age (y): mean/median n/r; range 14–79 | • Group 2: | celiac vs CO IgA-AGA | 55 | 45 | 0 | 109 | 55 | 100 | 100 | 70.8
| • case control | • % F: 71 | • 57 pts with non-CD conditions: Crohn's disease (n=38), ulcerative colitis (n=5), lymphoma (n=7), Whipple's disease (n=1), irritable bowel disease (n=6) | celiac vs CO IgG-AGA | 78 | 22 | 18 | 91 | 78 | 83.5 | 81.3 | 80.5
| Ethnicity: | | • age: n/r | celiac vs CO Ig-AGA | 92 | 8 | 5 | 104 | 92 | 95 | 96 | 90
| • n/a
| Population Type:
| • n/a
| Reference test:
| endoscopic biopsy
| First test:
| • n/r
| Controls biopsied:
| yes, except pts with ulcerative colitis
| Biopsy criteria:
| Roy-Choudhury criteria; partial or total VA
| Checked IgA def.
| yes
| Studied tests
| AGA-IgA; AGA-IgG; Ig AGA total Ig; EMA IgA (ME); JAB IgA
| Methodology:
| for AGA-IgA and IgG: ELISA; for Ig-AGA, EMA, JAB: IF
| Cut-off:
| for AGA-IgA and IgG: mean±2 SD of control absorbance index values; for Ig AGA: endpoint still generating a pertubular and a periglomerular reticular pattern; for EMA: results considered when a characteristic honeycomb pattern was observed around the smooth muscle; for JAB: IF at a dilution of 1:5 in phosphate-buffered saline
Sblaterro, 2000 Italy | Publication type: | Celiac Group 1 | Group 1: | celiac vs CO EMA | 60 | 5 | 0 | 170 | 93 | 100 | 100 | 97
| • journal | • 65 pts with biopsy proven CD | • 150 healthy donors and 20 pts with Crohn's disease (biopsy proven non-CD enteropathies or normal mucosa) | celiac vs CO IgG GP-tTG | 40 | 25 | 3 | 167 | 61 | 98 | 93 | 87
| Study design: | • age (y): median 12, range 2–60 | • age: mean/media n/r; range 12–60 y | celiac vs CO IgA GP-tTG | 53 | 12 | 3 | 167 | 84 | 98 | 94.6 | 88
| • case control | • % F: 52.3 | • % F: 44 | IgG/IgA GP-tTG | 58 | 7 | 6 | 164 | 90 | 96 | 91 | 98
| Ethnicity: | | | celiac vs CO IgG HR-tTG | 44 | 21 | 7 | 163 | 67.6 | 96 | 86.3 | 88.6
| • n/a | | | celiac vs CO IgA HR-tTG | 59 | 6 | 1 | 169 | 91.5 | 99 | 98.3 | 96.6
| Population Type: | | | IgG/IgA HR-tTG | 64 | 1 | 8 | 162 | 98.5 | 95 | 88.9 | 99.4
| • n/a
| Reference test:
| n/r
| First test:
| • biopsy
| Controls biopsied:
| ESPGHAN
| Biopsy criteria:
| ESPGHAN
| Checked IgA def.
| yes
| Studied tests
| EMA-IgA; GP-tTG IgG and IgA; HR tTG
| Methodology:
| for tTG: ELISA; for EMA: IF
| Cut-off:
| normal values for IgA HR-tTG were taken as <13% and for IgG HR-tTG <30%; normal values for IgA GP-tTG were taken as <7% and <16%
Sulkanen, Collin, et al. 1998 Finland | Publication type: | Celiac Group 1 | Group 1: | celiac vs control IgA-HU | 78 | 12 | 0 | 95 | 84.8 | 100 | 100 | 87
N.B: used adult group of Sulkanen, Collin, et al., 1998; more complete data located in Sulkanen, Halttunen, et al. 1998 | • journal | • 92 consecutive adult pts with biopsy-proven CD | • 95 disease controls with biopsy proven non-CD | celiac vs control IgG-HU | 11 | 81 | 0 | 95 | 12 | 100 | 100 | 54
| Study design: | • age (y): median 43; range 20–72 | enteropathies: 52 undergoing gastroscopic exam for dyspepsia; 14 with Crohn's disease, 29 with ulcerative colitis | celiac vs control IgA-ARA | 72 | 20 | 0 | 95 | 78.2 | 100 | 100 | 82.6
| • case control | • % F: 71.7 | • age (y): median 44; range 16–76 | celiac vs control IgG-ARA | 12 | 80 | 2 | 93 | 13 | 98 | 85.7 | 53.7
| Ethnicity: | | | celiac vs control IgA-AGA | 74 | 18 | 13 | 82 | 80.4 | 86.3 | 85 | 82
| • n/a | | | celiac vs control IgG-AGA | 35 | 57 | 3 | 92 | 38 | 96.8 | 92 | 61.7
| Population Type:
| • n/a
| Reference test:
| n/r
| First test:
| • n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| subtotal or severe partial VA, crypt hyperplasia, increased IEL
| Checked IgA def.
| yes (4 pts with CD and 1 CO had IgA deficiency)
| Studied tests
| HU IgA; HU IgG; ARA IgA and IgG; AGA IgA and IgG
| Methodology:
| for AGA ELISA; for ARA IF; for HU IF using HU
| Cut-off:
| HU-Ab positivity included a specific honey-comb IF around the smooth-muscle fibres; AGA IgA - cut off level-0.2 EU/mL; AGA IgG cut off level - 10.0 EU/mL; ARA test was considered positive when the characteristic R1-type ARA pattern was found
Sulkanen, Halttunen, et al. 1998 Finland | Publication type: | Celiac Group 1 | Group 1: | CD group1 vs CO IgA-tTG | 129 | 7 | 13 | 194 | 95 | 93.7 | 90.8 | 96.5
| • journal | • 136 consecutive pts with untreated CD (biopsy proven) | • 154 disease CO with suspicion of CD but biopsy proven non-CD | CD group1 vs CO IgA-EMA | 126 | 10 | 1 | 206 | 92.6 | 99.5 | 99.2 | 94.9
| Study design: | • age (y): median 10.7, range 0.8–69.3 | • age (y): median 10, range 0.8–76.0 | CD group1 vs CO IgA-ARA | 125 | 11 | 8 | 199 | 92 | 96.1 | 94 | 94.7
| • case control | • % F: n/r | • % F: n/r | CD group1 vs CO IgA-AGA | 115 | 21 | 38 | 169 | 84.5 | 81.6 | 75.2 | 89
| Ethnicity: | Celiac Group 2 | | CD group1 vs CO all IgG-AGA | 94 | 42 | 55 | 152 | 69 | 73.4 | 63 | 78.3
| • n/a | • 38 pts with CD on GFD of a median duration 48 mos
| Population type: | • age: median, range n/r
| • n/a | • % F: n/r
| Reference test: | Celiac Group 3
| Watson capsule | • 18 pts on a gluten-challenge
| First test: | • age: median, range n/r
| • n/r | • % F: n/r
| Controls biopsied: | • 11 pts after reintroduction of a GFD (group 4)
| • yes | • age (y): median, range n/r
| Biopsy criteria: | • % F: n/r
| ESPGAN
| Checked IgA def.
| yes (n=14)
| Studied tests
| IgA tTG; IgA EMA; IgA-ARA; IgA-AGA; IgG-AGA
| Methodology:
| tTG-source n/r ELISA; IgA-EMA-HU; IgA and IgG-AGA-ELISA; IgA ARA-IF)
| Cut-off:
| for IgA tTG cut off level-10 AU
Tesei, 2003 Argentina | Publication type: | Celiac Group 1 | Group 1: | CD vs CO: HU-anti-tTG IgA | 225 | 25 | 9 | 167 | 91 | 96 | 97 | 87
| • journal | • 250 consecutive pts with biopsy proven CD | • 176 biopsy proven non-CD disease controls: chronic diarrhea (n=78), chronic microcitic anemia (n=33), first-degree relatives of index cases (n=32), healthy individuals (n=11), malabsorption (n=4), miscellaneous (n=12), undernutrition (n=6) | CD vs CO: EMA | 214 | 36 | 0 | 176 | 86 | 100 | 100 | 83
| Study design: | • age (y): mean 39, range 13–79 | • age (y): mean 40, range 17–83 | CD vs CO: AGA IgA | 159 | 91 | 14 | 162 | 64 | 92 | 92 | 64
| • case control | • % F: 74 | • % F: 75 | CD vs CO: AGA IgG | 210 | 40 | 25 | 151 | 84 | 86 | 89 | 79
| Ethnicity:
| • n/a
| Population Type:
| • n/a
| Reference test:
| endoscopic biopsy
| First test:
| Simultaneously
| Controls biopsied:
| yes
| Biopsy criteria:
| Marsh 2 to 4 - with confirmation
| Checked IgA def.
| yes (11 pts were diagnosed as IgA deficient having dermatitis herpetiformis)
| Studied tests
| HU-anti-tTG IgA-HR; EMA-IgA; AGA-IgA; AGA-IgG
| Methodology:
| for HU-anti-tTG, ELISA; for EMA, ME IF; for AGA, ELISA
| Cut-off:
| for HU-anti-tTG - 7 AU/mL; for AGA - 20 AU/mL; for EMA - florescence at dilution of 1:5
Troncone, 1999 Italy | Publication type: | Celiac Group 1 | Group 1: | CD vs CO: anti-tTG IgA | 44 | 4 | 1 | 62 | 91.7 | 98 | 98 | 94
| • journal | • 48 biopsy proven CD pts | • 63 biopsy proven non-CD disease controls: chronic diarrhea (n=16), failure to thrive (n=14), Crohn's disease (n=10), cow's milk protein allergy (n=5), GERD (n=5), recurrent abdominal pain (n=4), sideropenic anemia (n=4), hepatatis C (n=3), Cystic fibrosis (n=2) | CD vs CO: anti-tTG IgG | 11 | 37 | 1 | 62 | 23 | 98 | 92 | 63
| Study design: | • age (y): mean 5.7, range 0.9–20 | • age (y): mean 4.2, range 1.1–17
| • case control | • % F: 58 | • % F: 49
| Ethnicity: | Celiac Group 2
| • n/a | • 33 pts who were on GFD of at least 2 y
| Population Type: | • age (y): mean 7.3, range 4.3–18
| • n/a | • % F: 60.6
| Reference test: | Celiac Group 3
| n/r | • 10 pts from group 2 who were reintroduced to gluten-containing diet
| First test:
| • n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| ESPGAN
| Checked IgA def.
| yes (none of celiac or CO suffered from IgA deficiency)
| Studied tests
| anti-tTG IgA; anti-tTG IgG; IgA EMA
| Methodology:
| for tTG-GP, ELISA; for EMA, ME IF
| Cut-off:
| for anti-tTG - at the 97th percentile of the control group (9% of the reference serum for IgA and 60% - for IgG); for EMA - as the highest dilution giving a positive result (a thin fluorescent network around the smooth muscle fibres)
Valdimarsson, 1996 Sweden | Publication type: | Celiac Group 1 | Group 1: | celiac vs CO IgA EMA | 14 | 5 | 0 | 125 | 74 | 100 | 100 | 96
| • journal | • 19 pts with CD (biopsy-proven) out of 156 pts referred for symptoms suspicious for CD | • 137 pts with biopsy proven non-CD; 5 had IgA deficiency and 7-dermatitis herpetiformis | celiac vs CO IgA AGA | 15 | 4 | 38 | 87 | 79 | 70 | 28 | 96
| Study design: | • age: n/r | • age: n/r
| • cohort | • % F: n/r | • NB: pts with IgA deficiency and dermatitis herpetiformis were excluded from the analysis of sensitivity, specificity, so that CO group was composed of 125 pts
| Ethnicity:
| • n/a
| Population Type:
| • n/a
| Reference test:
| Watson capsule in 91 pts; fiberoptic endoscopy - in 65 pts
| First test:
| • biopsy
| Controls biopsied:
| • yes
| Biopsy criteria:
| Alexander's classification; partial or subtotal VA
| Checked IgA def.
| yes (5 had IgA deficiency)
| Studied tests
| IgA AGA; IgA EMA
| Methodology:
| for AGA, ELISA; for EMA, IF ME
| Cut-off:
| for AGA-IgA, 30 units (>92nd percentile in healthy blood donors); for AGA-IgG, 20 units (>91.3th percentile in healthy blood donors); for IgA EMA, characteristic honeycomb pattern was observed around the smooth muscle
Valentini, 1994 Italy | Publication type: | Celiac Group 1 | Group 1: | celiac vs CO IgA EMA | 99 | 1 | 0 | 30 | 99 | 100 | 100 | 96.7
| • journal | • 100 consecutive adult untreated pts with CD (biopsy proven) | • 30 disease controls (CO) with biopsy proven non-CD conditions: ulcerative colitis (n=8), gastric lymphoma (n=8), Crohn's disease (n=5), Whipple disease (n=3), IBS (n=3), giardiasis (n=2), Graves disease (n=1) | celiac vs CO IgA/IgG AGA | 92 | 8 | 3 | 27 | 92 | 90 | 96.8 | 77.1
| Study design: | • age (y): mean 37.4+-15.4, range 17–79 | • age (y): mean 40+-13, range 18–60
| • case control | • % F: 77 | • % F: 47
| Ethnicity: | Celiac Group 2
| • n/a | • 33 pts out of 100 group 1 who were on GFD of at least 6 mos (mean 9.9 mos, range 6–12 mos);
| Population Type:
| • n/a
| Reference test:
| multipurpose biopsy tube, endoscopic
| First test:
| • simultaneously
| Controls biopsied:
| • yes
| Biopsy criteria:
| partial VA or greater
| Checked IgA def.
| n/r
| Studied tests
| IgA-AGA; IgG-AGA; IgA-EMA ME
| Methodology:
| for IgA/IgG AGA, ELISA; for IgA-EMA, IF
| Cut-off:
| lower limit of AGA positive was 1 EU, based on the mean+-2 SD of the results obtained in a large series of healthy adults; IgA-EMA identified by their reticulin-like staining of the smooth muscle; sera containing antibody at a titre of 1:5 or greater were considered to be positive
Vitoria, 2001 Italy | Publication type: | Celiac Group 1 | Group 1: | celiac vs CO: tTG | 40 | 2 | 0 | 28 | 95 | 100 | 100 | 93
| • journal | • 42 biopsy proven CD pts | • 28 biopsy proven non-CD disorders | celiac vs CO: EMA | 42 | 0 | 0 | 28 | 100 | 100 | 100 | 100
| Study design: | • age: mean 4.2±4.2 y | • age: mean 6.1+-5.2 y
| • case control | • % F: n/r | • % F: n/r
| Ethnicity:
| • n/a
| Population Type:
| • n/a
| Reference test:
| n/r
| First test:
| • n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| subtotal VA
| Checked IgA def.
| n/r
| Studied tests
| IgA tTG-ab; IgA EMA
| Methodology:
| tTG-HR, ELISA; IgA-EMA, IF ME
| Cut-off:
| for tTG, values of 9 U/mL and more were considered positive; for EMA, reticular pattern of fluorescence in the muscular mucosa at a dilution of serum 1:5 were considered positive
Vogelsang, 1995 Austria | Publication type: | Celiac Group 1 | Group 1: | celiac 1 vs control 1 | 40 | 9 | 9 | 44 | 81.6 | 83 | 81.6 | 83
| • journal | • 49 untreated biopsy-proven CD | • 53 biopsy-neg controls; median age 31; range 15–79; Crohn's (17); IBS (16); lactase def (7); fibroma (1); duodenitis (1); gastroparesis (3); gastritis (2); chron pancr (1); UC (1); coll colitis (1) | | 36 | 13 | 14 | 39 | 73.5 | 73.6 | 72 | 75
| Study design: | • age: median 35; range 17–75 | | | 49 | 0 | 0 | 53 | 100 | 100 | 100 | 100
| • cohort
| Ethnicity:
| • n/r
| Population Type:
| • suspected CD
| Reference test:
| biopsy
| First test:
| • endoscopic biopsy distal duodenum or Baumgartner-Classen capsule from duodenojejunal flexure
| Controls biopsied:
| • yes
| Biopsy criteria:
| modified ESPGAN; flat mucosa; crypt hyperplasia raised IELs
| Checked IgA def.
| yes; no cases found
| Studied tests
| IgA-AGA; IgG-AGA; IgA-EMA
| Methodology:
| ELISA; >95th percentile; ME
| Cut-off:
| AGA 0.2 AU/mL
Volta, 1995 Italy | Publication type: | Celiac Group 1 | Group 1: | celiac vs CO IgA-EMA ME | 57 | 3 | 0 | 100 | 95 | 100 | 100 | 97.1
| • journal | • 60 untreated pts with biopsy-proven CD | • 100 disease CO (biopsy proven non-CD in disease CO): ulcerative colitis (n=25), Crohn's disease (n=35), various other GI diseases (n=40) | celiac vs CO IgA-EMA HU | 57 | 3 | 0 | 100 | 95 | 100 | 100 | 97.1
| Study design: | • age (y): median 41, range 14–68 | • age (y): median 44, range 25–70
| • case control | • % F: 70 | • % F: 68
| Ethnicity: | Celiac Group 2 | Group 2:
| • n/a | • 36 pts with CD on GFD of 12 mos duration | • 100 healthy CO (not biopsied)
| Population Type: | | • age: median, range n/r
| • n/a | | • % F: n/r
| Reference test:
| n/r
| First test:
| • n/r
| Controls biopsied:
| • only disease CO
| Biopsy criteria:
| Roy-Choudhury criteria
| Checked IgA def.
| n/r
| Studied tests
| IgA-EMA on ME; IgA-EMA on HU
| Methodology:
| IF
| Cut-off:
| staining of the endomysium around the smooth muscle was considered as a positive result
Whelan, 1996 Ireland | Publication type: | Celiac Group 1 | Group 1: | UTCD vs CO: HUVEC | 25 | 0 | 0 | 36 | 100 | 100 | 100 | 100
| • journal | • 25 untreated CD (biopsy-proven) — (UTCD) | • 20 disease CO (biopsy proven non-CD in disease CO) - 10 pts with ulcerative colitis and 10 - with Crohn's disease | UTCD vs CO: EMA ME | 25 | 0 | 0 | 36 | 100 | 100 | 100 | 100
| Study design: | • age: median, range n/r | • age: median, range n/r | UTCD vs CO: ARA | 21 | 4 | 0 | 36 | 84 | 100 | 100 | 90
| • case control | • % F: n/r | • % F: n/r
| Ethnicity: | Celiac Group 2 | Group 2:
| • n/a | • 16 treated CD on GFD — TCD | • 16 CO with normal intestinal mucosa
| Population Type: | • age: median, range n/r | • age: median, range n/r
| • n/a | • % F: n/r | • % F: n/r
| Reference test:
| n/r
| First test:
| • n/r
| Controls biopsied:
| • only disease CO
| Biopsy criteria:
| subtotal VA
| Checked IgA def.
| n/r
| Studied tests
| HUVEC IgA - human umbilical vein endothelial cells; EMA IgA; (ME) ARA IgA (rat liver); only EMA used for analysis
| Methodology:
| HUVEC - IF; EMA - IF; ARA - IF
| Cut-off:
| n/a
Wolters, 2002 Netherlands | Publication type: | Celiac Group 1 | Group 1: | CD vs CO: IgA AGA | 43 | 9 | 10 | 39 | 83 | 86 | 81 | 81
| • journal | • 52 pediatric pts with biopsy proven CD | • 49 disease CO pts with biopsy proven non-CD | CD vs CO: IgG AGA | 43 | 9 | 7 | 42 | 83 | 80 | 86 | 82
| Study design: | • age: mean 4.0 y, range 1.1–14.4 y | • age: mean 5.1 y, range 0.8–19.2 y | CD vs CO: IgA EMA | 48 | 4 | 5 | 44 | 92 | 90 | 90.5 | 92
| • cohort | • % F: 73 | • % F: 41 | CD vs CO: anti-GP-tTG IgA | 50 | 2 | 4 | 45 | 96 | 92 | 92.6 | 95.7
| Ethnicity: | | | CD vs CO: anti-h-tTG IgA | 50 | 2 | 0 | 49 | 96 | 100 | 100 | 96
| • n/a
| Population Type:
| • n/a
| Reference test:
| endoscopic biopsy
| First test:
| • n/r
| Controls biopsied:
| • yes
| Biopsy criteria:
| subtotal VA with crypt hyperplasia
| Checked IgA def.
| n/r
| Studied tests
| IgA-AGA; IgG-AGA; IgA-EMA; IgA-GP-tTG; IgA-HU-tTG
| Methodology:
| for AGA-ELISA; for EMA—IF ME; for tTG - ELISA
| Cut-off:
| for AGA: Ab titers were considered positive if IgA-AGA exceeded 4 U/mL and IgG-AGA exceeded 150 U/mL; for EMA - fluorescence in the muscularis mucosa at a serum dilution equal to or greater than 1:5

### HLA DQ2/DQ8

Evidence Table 2. Case-control study evidence for the use of HLA as a marker of CD

Author, Year, Location | Study Design | Study Population | Control Population | Results
| | | | Celiac Group | Control
| | | | | Group 1 | Group 2
Iltanen, 1999, Finland | • case control | • 21 children with biopsy-confirmed CD | Group 1: | • DQ2: 19 (90.48) | • DQ2: 29.85
| • monoclonal antibodies used to stain jejunal IELs and mucosal HLA-DR; DQA1*0501 and DQB1*0201 alleles determined | • CD criteria: ESPGAN | • 67 ethnically-, age-matched pts with biopsy-negative CD | • DQ8: n/a | Sens: 0.90
| | • mean age: 6.1 y, range 0.5–16.3 y | • ethnicity: n/r | • DQ2 or 8: n/a | Spec: 0.70
| | • % F: n/r | | Prevalence of CD: 0.24 | PPV: 0.49
| | • ethnicity: n/r | | | NPV: 0.96
| | | | | • DQ8: n/a
| | | | | • DQ2 or 8: n/a
Sacchetti, 1998, Southern Italy | • case control | • 122 children with biopsy-confirmed CD | Group 1: | • DQ2: 106 (86.89%) | • prevalence of CD: 0.79 | • Prevalence of CD: 0.51
| • used PCR to examine prevalence of HLA heterodimer and HLA DRB104 alleles in healthy subjects, in CD-affected children, and in other age-matched subjects affected by confounding disease | • CD criteria: ESPGAN | • 32 age-matched pts with GI symptoms but negative biopsy for CD | • DQ8: n/a | • DQ2: 6 (18.75%) | • DQ2: 31 (26.72%)
| | • ethnicity: Italian | • Ethnicity: Italian | • DQ2 or 8: n/a | Sens: 0.87 | Sens: 0.87
| | | Group 2: | | Spec: 0.81 | Spec: 0.73
| | | • 116 ethnically-matched healthy adult controls | | PPV: 0.95 | PPV: 0.77
| | | | | NPV: 0.62 | NPV: 0.84
| | | | | • DQ8: n/a | • DQ8: n/a
| | | | | • DQ2 or 8: n/a | • DQ2 or 8: n/a

## Celiac 2: Incidence and Prevalence of CD

### Incidence of CD in the General Population

Evidence Table. 3 Incidence of CD in the general population

Study, year; country | Group at risk | Case ascertainment | Screening | Incidence | Other observations
Bode, 1996 Denmark | Region: | Institution(s): | | Outcome measures: | Women:
| County of Copenhagen | sole 3 teaching hospitals + clinic of region | | cumulative incidence avg incidence rates adjusted for age/sex | Crude incidence:
| Period: | Register(s): | | Results: | 1.55/100,000
| 1976-1991 retrospective | Discharged Dx w ICD 269-0.01; all small bowel biopsy from path depts; case register of all celiacs | | # cases: | Lifetime cumulative incidence:
| Age groups: | Verification of accuracy: | | 101 (64F/37M) | 55.8/100,000
| all adults>15 | review of case records | | Characteristics of cases: | Men:
| Size: | Dx Criteria: | | median age at Dx: | Crude incidence:
| 480,581 in 1976; 503,283 in 1992 | at least 1 biopsy; good response to GFD; gluten challenge with re-biopsy if Dx uncertain | | 40.1 y (range 16–81) | 0.96/100,000
| | % capture: | | crude incidence: | Lifetime cumulative incidence:
| | | | 1.27/100,000 | 35.3/100,000
| | | | cumulative incidence: | Prevalence (1992):
| | | | 19 y: 198/1000 births | 45.9/100,000
Collin 1997 Finland | Region: | Institution(s): | | Outcome measures: | Median age at Dx:
| Tampere City | Sole 3 centers that perform gastroscopy; The University Hospital. The City Hospital and the local health centre | | Prevalence: All adult CD pts living in Tampere on Dec 31 1994 per 100 000 population | 39 y (range 1–80)
| Period: | Register(s): | | 5-y Incidence: All adult CD pts dx'ed between 1975 and 1994 per 100,000 pop. | Prevalence in 1994:
| 1975-94 | Membership list of local Coeliac Society | | Results: | 204/100,000 (95% CI 181–231)
| Age groups: | Verification of accuracy: | | # cases: | Mode of presentation:
| Adult | All case records and specimen of CD pts were verified | | 301 cases (222 F/79 M) | Apparent symptoms: 24%
| Size: | Dx Criteria: | | Characteristics of cases: | Minor symptoms: 37%
| 121,000 in 1970; 147,000 in 1994 | Subtotal or severe partial VA and crypt hyperplasia; clinical or histological improvement on GFD | | Crude incidence (/100,000 pop/yr): | Screening: 27%
| Note: | % capture: NR | | 1975-79: 1.6 | Chance at endoscopy: 13%
| Screening of high-risk groups in effect Systematic small bowel biopsy during gastroscopy | | | 1980-84: 6.8 | Causes for increased incidence:
| | | | 1985-89: 13 | Use of serologic screening Performance of small bowel biopsy on all pts undergoing gastroscopy Ability of all GP to refer pts to gastroscopy
| | | | 1990-94: 17.2
| | | | Cumulative incidence: NR
Corrao, 1996 Italy | Region: | Institution(s): | | Outcome measures: | RR according to gender (95% CI):
| Provinces of Turin, Cuneo, Brescia, Umbria region, Sardinia region | Dx lists of peds, med, GI depts in all hosp; Dx lists leading Italian hosp | | crude incidence: #new Dx/yr/100,000 pop | Male: 1.0
| Period: | Register(s): | | cumulative incidence: #cases over period/100,000 births | Female: 1.90 (1.48, 2.45)
| 1990-91 prospective vs retrospective | National Health Service records; local Italian Coeliac Society | | Results: | RR according to age (95% CI):
| Age groups: | Verification of accuracy: | | # cases: | 0–15: 1.0
| All ages | capture-recapture method | | 270 (181F/89M) | 16–39:0.33 (0.25–0.44)
| Size: | Dx Criteria: | | Characteristics of cases: | 40–59:0.21 (0.15–0.30)
| Italian population census in 1991 | biopsy without challenge in 47.2% | | mean age at Dx: | >60: 0.11 (0.06–0.18)
| 6,339,194 in 1991 (11.0% Italy); 107,048 live births (9.4% Italy) | ESPGAN in 52.8% | | children 3.7; adults 34; overall 21
| | % capture: | | Crude incidence:
| | 85.6% | | 2.13/100,000/y
| | Exclusion(s): | | Cumulative incidence (/10,000 births):
| | pts residing outside Dx area | | 2 y: 5.75
| | | | 5 y: 8.08
| | | | 10 y: 10.30
| | | | 15 y: 11.42
Hawkes, 2000 England | Region: | Institution(s): | | Outcome measures:
| South Glamorgan | sole 3 teaching hospitals in Cardiff | | Crude incidence: age-weighed avg/100,000 pop
| Period: | Register(s): | | Results:
| 1980-95 retrospective | Local Celiac Society, letters to GP from consultants | | # cases:
| Age groups: | Verification of accuracy: | | 137 (98F/39M)
| all ages | pathology & dietetic records from the 3 Cardiff teaching hospitals | | Characteristics of cases:
| Size: | Dx Criteria: | | mean age at Dx:
| Registrar General mid-yr estimates for total pop, pop <16yr, total live births 415,900 in 1995 | ESPGAN | | children 5.3 yrs (range 0.9–14.9); adults 49.1 yrs (range 19.9–88.2)
| | % capture: | | Crude incidence:
| | 100% | | children (/100,000/yr):
| | | | 1981-85: 2.08
| | | | 1986-90: 2.53
| | | | 1991-95: 2.15
| | | | adults (/100,000/yr):
| | | | 1981-85: 1.32
| | | | 1986-90: 2.15
| | | | 1991-95: 3.08
| | | | Cumulative incidence: NR
Hoffenberg 2003 US | Region: | | Intervention: | Outcome measures: | RR according to gender:
| Denver Colorado | | HLA type newborn; follow-up of selected genotypes | Time to the event of evidence of CD; Cumulative probability of being event-free for the entire population; Cumulative incidence of evidence of CD, stratified by genotype (DR3/3; DR3/x, DRx/x); RR evidence of CD by genotype | Female: 3.34 (95% CI 1.00–10.9)
| Period: | | Follow-up: | Results: | RR according to ethnicity:
| 1993-99 prospective | | CD serology at 9, 15 and 24 months of age, then yearly. | # cases: | Non-hispanic whites: 3.33 (0.7–12.5)
| Age groups: | | If positive tTG on 2 separate occasions, or if positive tTG plus clinical suspicion, evaluation for small bowel biopsy. | 40 tTG pos at least once; 19 with evidence of CD; 10 biopsy-confirmed; 9 with pos tTG at least twice | RR according to genotype
| Birth to 7 y; | | CD serology: | Characteristics of cases: | (Compared to HLA DR3 negatives):
| 987 for at least 1 y; | | EMA IgA 1993-98; tTG IgA 1998-99; Retesting of EMA positive samples with tTG once test available; Total IgA; tTG IgG used on IgA deficients. | 13F/6M | HLA-DR3/3: 9.1 (95% CI 1.7–48)
| 386 for at least 5 y | | Dx criteria: | Mean age 4.6 (range 2.6–6.5) | HLA-DR3/x: 5.6 (95% CI 1.5–21)
| Size: | | Either positive tTG plus biopsy (Marsh 2 or greater), or two consecutive tTG positives 6 months apart | 84% non-hispanic whites
| Sample from 22 346 newborns screened for HLA, i.e. 987 infants from one institution (St Joseph's Hospital) | | | Crude incidence: NR
| Ethnicity: | | | Cumulative incidence at age 5:
| 56% non Hispanic white | | | 9/1000 births (95% CI 4–20)
| 30% Hispanic | | | Cumulative incidence at age 5 according to genotype:
| 7% African American | | | HLA-DR3/3: 32/1000 (95% CI 10–110)
| 2% Asian American | | | HLA-DR3/x: 34/1000 (95% CI 30–117)
| 5% biracial/other | | | HLA-DR3 neg: 3/1000 (95% CI 0–27)
| Genotypes:
| HLA-DR3/3; DR3/4, DQB1*0302; DR4, DQ8; DR5/7
Ivarsson, 2003, Sweden | Region: | Institution(s): | | Outcome measures: | RR according to age:
Duplicate: | Entire Sweden | Prospective reporting from 9 departments of pediatrics | | Incidence rate: #new cases/100,000 PYs; cumulative incidence: # cases up to age/1000 birth in same cohort | 0–2 y: 1.0
Ivarsson Acta Paediatrica 2000;89:165 | Period: | Register(s): | | Results: | 2–15: 0.031 (0.022–0.043)
| 1973-97 prospective and retrospective | Sweden's National Child health program; central register of CD cases in children <15; | | # cases of CD: | RR according to gender:
| Age groups: | Statistics Sweden | | 2151 (1340F/811M) | M: 1.0
| Children | Verification of accuracy: | | Characteristics of cases: | F: 1.9 (1.7–2.1)
| • 0–2 y | local registers | | Crude incidence (/100,000PY): | RR according to period:
| • 2–15 y | % capture: | | 1973-84: 0–2: 65 (57–74) | 1973-84: 1.0
| Size: | | | 1987-94: 0–2: 198 (186–210) | 1985-95 1.7 (1.2–2.5)
| 258,683 in 1973; 623,439 in 1991 | | | 1997: 0–2: 51 (36–70) | 1996-97 6.8 (4.5–10)
| Dx Criteria: | | | Cumulative incidence at 2 y:
| ESPGAN | | | 1995: 1.7 (95% CI 1.3–2.1)/1000 births
Jansen, 1993 Netherlands | Region: | Institution(s): | | Outcome measures: | Prevalence
| Entire country | Register(s): | | Incidence: # new cases/100,000 pop/yr; | 1990: 7.9/100,000 (95% CI 6.7–9.3)
| Period: | Dutch Coeliac Disease Society for 1992 | | Prevalence rate: # cases/100,000 | 1991: 11.3/100,000 (95% CI 9.5-1.0)
| 1975-91 retrospective | Verification of accuracy: | | Results: | 1992: 12.7/100,000 (95% CI 11.0–14.5)
| Age groups: | Dx criteria: at least 1 biopsy | | # cases: 1983
| all ages | % capture: 97% | | Characteristics of cases:
| Size: | | | Crude incidence (/100,000/yr):
| Central Bureau for statistics 14,892,574 in 1990 | | | 1981-88: 0.65
| | | | 1988-90: 0.8
| | | | 1991-92: 1.0
Lopez Rodriguez, 2003 Spain | Region: | Institution(s): | | Outcome measures: | RR according to period:
| Caceres, south-west Spain | San pedro de Alcantara hospital, | | crude incidence: # cases/100,000 pop/yr | 1981-90: 1
| Period: | Province referral center for biopsy | | Results: | 1991-99: 2.31 (1.61–3.31)
| 1981-99 retrospective | Register(s): | | # cases: | RR according to age:
| Age groups: | Verification of accuracy: | | 157 (90F/67M) | 4–15 y: 1.0
| Children 0–14 y; Spanish National Statistics Institute | clinical records | | Characteristics of cases: | 0–4 y (1981-90): 18.2
| Size: | Dx Criteria: | | mean age at Dx: | 0–4 y (1991-99):42.04
| 65 137 children in 1998; | ESPGAN | | 1981-90: 37.4+/-47.4 mo | % with typical clinical presentation:
| 98 641 in 1986 | % capture: | | 1991-99:43.9+/-43.7 mo | 1981-90: 83.6%
| 66 496 in 1996 | | | Crude incidence (/100,000/yr): | 1991-99: 58.3%
| | | | 1981-90: 6.87 (5.26–8.83) | Significant positive correlation between age at Dx and age of introduction of gluten:
| | | | 1991-99: 16.04 (12.99–19.59) | 1981-90: r=0.296 , p=0.0211
| | | | | 1991-99: r= 0.293, p=0.0037
Magazzu, 1994 Sicily | Region: | Institution(s): | | Outcome measures:
| Entire country | All 4 Sicilian centers of pediatric GI in Catania, Messina and Palermo | | cumulative incidence rate by birth cohort: #new cases/#live birth in same birth cohort (95%CI);
| Period: | Register(s): | | incidence density: # cases/(#birth in cohort/#yrs of follow up)/15 y obs period
| 1975-89 retrospective | Registrations from all 62 Sicilian health authorities; pt list of each GI pediatric centers; pt list of gluten-free products consumption | | Results:
| Age groups: | Verification of accuracy: | | # cases:
| children | Chart review of cases; personal interviews; contact of family pediatrician | | 1074 (607F/467M)
| Size: | Dx Criteria: | | Characteristics of cases:
| 69,945 births in 1989 | ESPGAN | | 99.4% Caucasian
| | % capture: | | Crude incidence:
| | Exclusion(s): | | Cumulative incidence:
| | no proof of remission on GFD; at least subtotal VA on biopsy; pts not traced back (1.5%) | | 1980 birth year: 1.19/1000 child.yr, 95% CI 0.96–1.45
| | | | 1984 birth yr: 1.16/1000 child.yr, 95% CI 0.92–1.42
| | | | 1989 birth yr: 0.13 /1000 child.yr, 95% CI 0.06–0.23
Maki, 1990 Finland | Region: | Institution(s): | | Outcome measures: | Significant correlation between the age at Dx and duration of breastfeeding
| Tampere City | Department of Paediatrics, University Central Hospital of Tampere | | Crude incidence: # cases/100,000pop/yr | Decreased incidence in 0–2; increased incidence in 2–15; increased subclinical presentation in children
| Period: | Register(s): | | Results:
| 1961-84 | nil | | # cases: 96
| Age groups: | Verification of accuracy: | | Characteristics of cases:
| Children | Questionnaire to pts and their parents; hospital medical records; Child health center charts | | Crude incidence:
| Size: | Dx Criteria: | | 1964-73: 10.12/100,000 PYs
| 131,394 live births 1960-84 | Small bowel biopsy; ESPGAN in 44% | | 1974-83: 3.46/100,000 PYs
| Exclusion(s): | % capture: NR | | 1960-84: 2.28/100,000 PYs
| Cases not born in a certain strict area around the city | | | Cumulative incidence:
Talley, 1994 US | Region: | Institution(s): | | Outcome measures: | 0–14:0.4/100,000PYs
| Olmstead County | Register(s): | | Results: | 15–44:0.7
| Period: | Rochester Epidemiology Project | | # cases: | 45–64:2.5
| 1960-90 retrospective all ages | Verification of accuracy: | | 28 (19F/9M) | >65 2.1
| Age groups: | Medical records reviewed; biopsy reviewed | | Characteristics of cases: | prevalence 1991: 21.8/100 000
| Size: | Dx Criteria: | | Crude incidence: | Median age at Dx:
| | % capture: | | Overall: 1.2 | median 50 (interQ range 35–62)
| | Exclusion(s): | | 1960-69: 0.9
| | living outside territory at time dx | | 1970-79: 0.7
| | | | 1980-90: 1.7
| | | | Cumulative incidence:
Weile, 1993 Denmark | Region: | Institution(s): | | Outcome measures:
| Copenhagen County | Register(s): | | Cumulative incidence:
| Period: | National Central register of Diagnosis 1977-87 Local register of pts admitted for SB biopsy Celiac Patient Society | | #cases/1000 birth in birth cohort
| 1960-88 retrospective | Verification of accuracy: | | Results:
| Age groups: | Data twice thoroughly evaluated | | # cases:
| children | % capture: | | 176 (103F/73M)
| Size: | | | Characteristics of cases:
| 1,972,864 live births | | | Crude incidence:
| Dx criteria: | | | 1988: 0.102/1000 births
| Biopsy-proven (90%); clinically suspected CD (10%) | | | Cumulative incidence:
| | | | median: 0.089/1000 live births (range 0–0.182)
| | | | age 5: 0.118/1000 births

### Prevalence and Incidence in the General Population—Different Geographic and Racial/Ethnic Populations

Evidence Table 4. Prevalence/incidence of CD in the general population

Author, Year, Location | Study Design | Patient Characteristics | Prevalence | | | | | | | | | | | | Comments
| | | Group 1 | Group 2 | Group 3 | Group 4 | Group 5 | Group 6 | Group 7 | Group 8
Borch, 2000 Sweden | Publication type: | Ethnicity: | first serology: 96 | | | | | | | | Not all systematically biopsied; only those with suggestive endoscopic features
Duplicate: no | journal | 459 Swedish; 17 Northern Europeans; outside of Northern Europe | confirmation serology: 7
| Study design: | Patient type/# screened: | biopsy proven: 9
| cross-sectional prevalence | n=2,000 healthy adults invited to participate in endoscopy study of relation of H.pylori to duodenitis; 482 agreed to participate
| Test/methodology: | Demographics:
| biopsy; IgA & IgG-AGA; IgA-EMA ME | age range: 34–75 y
| Biopsy criteria/description: | Incidence:
| Alexander Grade
| Confirmatory test:
| n/r
| Checked IgA def
| n/r
Carlsson, 2001 Sweden | Publication type: | Ethnicity: | 5.1% (35/690) had either EMA or AGA positive; (13/690) EMA alone: by biopsy: 1.6% (11/35/690) serology positives underwent jejunal biopsies, 11 of them became biopsy-confirmed CDs
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | unselected; all children born July 1992 through June 1993
| Test/methodology: | Demographics:
| AGA, cut-off at 25AU; indirect IF EMA, cut-off at titre >5; biopsy using Watson capsule | n=690 (out of 1287/3007 children initially contacted, excluding 22 known CD cases) mean age: 32 mos; range: 27–41 mos
| Biopsy criteria/description: | Incidence:
| used Waston capsule; revised ESPGAN? for classification: normal, subnormal (villous length/crypt length<2, increased number of inflammatory cells in the muscosa with or without damage to the surface epithelium and the brush border), or total VA (flat mucosa)
| Confirmatory test:
| biopsy
| Checked IgA def.
| n/r
Catassi, 1996, Italy | Publication type: | Ethnicity: | 1289/17201 (7.5%) AGA-IgG or IgA pos; confirmed with EMA=111/17201; biopsy on 98/111 was pos in 75 + 7 who had no biopsy but CD by various investigations
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | School age children
| Test/methodology: | Demographics:
| IgA or IgG-AGA | n=17,201; age range: 6–15 y
| Biopsy criteria/description: | Incidence:
| ESPGAN
| Confirmatory test:
| EMA and biopsy
| Checked IgA def.
| n/r
Catassi, 2000, Italy | Publication type: | Ethnicity: | 0.86% (18/2,096)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | general public, students
| Test/methodology: | Demographics:
| IgG-AGA (7 AU); IgA-AGA (15 AU); IgA-EMA indirect IF (1:5 dilution); biopsy | n=2,096; pedi
| Biopsy criteria/description: | age range: 11–15 y
| ESPGAN; Marsh; grade I = isolated increase gamma delta IEL count, grade II= increase gamma delta lymphocyte count with shortened villi/crypt hyperplasia, grade III= subtotal VA | % F: 49.5
| Confirmatory test: | Incidence:
| biopsy
| Checked IgA def.
| yes, 6 found
Collin, 2002 Finland | Publication type: | Ethnicity: | GERD: 0.61% (18/2974) | dyspepsia: 0.77% (41/5347) | CD: 5.33% (88/1650)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 1. GERD group: regurgitation or heartburn; 2. dyspepsia group; 3. suspected CD
| Test/methodology: | Demographics:
| biopsy | n=9,971; adolescent and adult
| Biopsy criteria/description: | median age: 58 y; range: 12–93 y
| ESPGAN | % F: 63.5
| Confirmatory test: | Incidence:
| biopsy
| Checked IgA def.
| n/r
Corazza, 1997 Republic of San Marino | Publication type: | Ethnicity: | by both EMA and biopsy: 1 in 559 pts, or 1.79 per 1,000 (0.18%)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | random sample stratified for age and sex
| Test/methodology: | Demographics:
| indirect IF EMA titre >1:5; biopsy | n=2,237; adult
| Biopsy criteria/description: | median age: 44 y; range, 20–87 y
| n/r | % F: 53.2
| Confirmatory test: | Incidence
| biopsy
| Checked IgA def.
| no, but mentioned as such that it could have caused some misclassification of pts, but the effect should be minimal given the powerful sensitivity and specificity of EMA test
Csizmadia 1999 Netherlands | Publication type: | Ethnicity: | 1.2% (75/6127) by IgA-EMA, 18/75 refused small bowel biopsy; 0.51% (31/75/6127) VA (CD) | | | | | | | | 26/27 with VA had the allele HLA-DQ2; prevalence 1:198 in children 2–4 y
Duplicate: no | Journal (research letter) | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 6,127 children between ages of 2–4 y general population
| Test/methodology: | Demographics:
| IgA-EMA (methodology n/r) | 6,127 pediatric pts
| Biopsy criteria/description: | age: range 2–4 y
| n/r | % F: n/r
| Confirmatory test: | Incidence:
| small bowel biopsy, subset of 27 had HLA typing for DQ2 | Time period: between May 1997-June 1998
| Checked IgA def.
| n/r
Dickey 1992, Ireland | Publication type: | Ethnicity: | By first serology: 5
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | healthy blood donors
| Test/methodology: | Demographics:
| IgA-AGA | n=443; adults, age range 18–65 y
| Biopsy criteria/description: | Incidence:
| no biopsy performed
| Confirmatory test:
| n/r
| Checked IgA def
| n/r
Fasano, 2003, USA | Publication type: | Ethnicity: | 1) at risk: a) 1st deg relatives-205/4508 (4.55%); children-54/1294 (4.17%); adults-151/3214 (4.70%); b) symptomatic adults-28/1910 (1.47%); children-53/1326 (4.00%) | | | | | | | | 116/350 biopsied
Duplicate: no | journal | 94% White; 3% Black; 1.5% Hispanic, 1% Asian, 0.5% other | 2) not at risk-1/4126 (0.75%); adults-27/2845 (0.95%); children-4/1281(0.31%); biopsy in EMA pos-Marsh I-0%; II-30/116 (25.9%); IIIa-46/116 (39.7%); IIIb-24/116 (20.7%); IIIc-16/116 (13.8%); HLA DQ2–76/98 (78%); DQ8–16/98 (16%); DQ2 and 8–6/98 (6%); all EMA pos were also tTG pos
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 9,019 at risk of CD; 4,126 not at risk
| Test/methodology: | Demographics:
| EMA-IF; ME or HUC; positive at 1:10; all positive EMA tested with human tTG ELISA positive at 2 SD above mean of healthy controls; HLA DQ2 and DQ8 | at risk: symptoms of CD (1,326 children, 1,909 adults); CD associated disorders; 4,508 1st deg relatives; 1,275 2nd deg relatives; not at risk: 2,000 blood donors (mean age 39 y, range 19–65 y); 1,119 school children (mean age 12.3 y, range 6–18 y); 1,007 adults and children for routine physical (mean age 39 y, and 13.7 y, range 19–71 y and 2–18 y, respectively)
| Biopsy criteria/description: | Incidence:
| Confirmation test:
| htTG; biopsy; also small subset 98 EMA positive and 114 EMA neg had HLA DQ2/8 tested
| Checked IgA def.
| •n/r
Green, 2000 USA | Publication type: | Ethnicity: | Biopsy proven: 9 | | | | | | | | Not all systematically biopsied; only those with suggestive endoscopic features
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | n=1,749 adults; suggestive endoscopic features of CD while undergoing routine endoscopy
| Test/methodology: | Demographics:
| EGD, biopsy | n/r
| Biopsy criteria/description: | Incidence:
| n/r
| Confirmatory test:
| n/r
| Checked IgA def.
| n/r
Grodzinsky, 1996 Sweden | Publication type: | Ethnicity: | By first serology: 124 | | | | | | | | IgA or IgG-AGA confirmed by having both and by biopsy; prevalence by IgA-EMA
Duplicate: no | journal | n/a | by confirmation serology: 11 | | | | | | | | n/r
| Study design: | Patient type/# screened: | by biopsy: 7
| cross-sectional prevalence | healthy adult blood donors
| Test/methodology: | Demographics:
| IgA-AGA; both IgA- and IgG-AGA | n=1,866; median age 38.5 y, range 18–64 y
| Biopsy criteria/description: | Incidence:
| n/r
| Confirmatory test:
| ?
| Checked IgA def.
| n/r
Hovdenak, 1999 Norway | Publication type: | Ethnicity: | Prevalence of CD in the screening group was 1:340 (7/2069); prevalence of test positivity: 83 of 2069 were positive for AGA; EMA was positive in 8 of these 83 pts; biopsy proven CD was diagnosed in 7 of these 8 pts | | | | | | | | Biochemical analysis showed iron deficiency in 2 pts, hypocalcemia in 1 pts and low serum zinc in 5 pts; 4 pts had osteoporosis and another 4 had decreased vitamin E serum concentration
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 2,069 healthy blood donors screened for CD; 1st level of screening: measuring of IgA and IgG AGA; 2nd level of screening: measuring IgA-EMA in AGA positives; 3rd level of screening - biopsy in IgA EMA positives
| Test/methodology: | Demographics:
| IgA and IgG-AGA, ELISA, cut-off levels: for IgA ≥ 0.35 and for IgG ≥ 0.90; IgA-EMA, IF, cut-off n/r | n=2,069; age: median 39 y, range 18–67 y
| Biopsy criteria/description: | M/F ratio: 1.65
| endoscopic biopsy; at least 3 biopsy specimens taken; classification as either normal, partial VA or subtotal VA | Incidence:
| Confirmatory test:
| biopsy
| Checked IgA def.
| n/r
Ivarsson, 1999 Sweden | Publication type: | Ethnicity: | Prevalence of CD was 5.3 per 1000 (10/1894); prevalence of newly diagnosed CD was at least 4 per 1000 (8/1892) - (1 woman with positive IgA EMA refused biopsy); as for the prevalence of test positivity: IgA and/or IgG AGA - positive in 23% (438/1892); IgA EMA - positive in 0.5% (9/1892); all CD pts had elevated IgA EMA | | | | | | | | CD was more common amongst women (7 F and 3 M) and the older age groups, with the highest prevalence in the interval 55–64 y - 50%
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 1,894 individuals taken randomly from 1994 WHO MONICA study population and screened for CD
| Test/methodology: | Demographics:
| IgA and IgG AGA - ELISA, cut-off n/r; IgA EMA - IF on a ME, cut-off dilution level varied from 1/20 to 1/320; positive if presence of characteristic reticulin-like staining pattern; serum IgA level measurement using routine nephelometric method, level below 0.05 gL was defined as IgA deficient | n=1,894
| Biopsy criteria/description: | age (y): median 50, range 25–74
| criteria for the diagnosis of CD was biopsy demonstrating enteropathy grade III to IV according to Alexander | % F: 50
| Confirmatory test: | Incidence:
| endoscopic biopsy
| Checked IgA def.
| yes, using routine nephelometric method; 0.2% (4/1892) pts were found to have IgA deficiency
Jager, 2001 Germany | Publication type: | Ethnicity: | Recent-onset IDDM (n=197): IgG AGA - 10.2%; IgA AGA - 7.6%; anti-tTG IgA - 9.7%; at least 1 antibody positive - 16.8% | First-degree relatives (n=882): IgG AGA - 5.6%; IgA AGA - 2.6%; anti-tTG IgA - 3.2%; at least 1 antibody positive- 7.3% | Healthy control subjects (n=150): IgG AGA - 3.2%; IgA AGA -2.0%; anti-tTG IgA - 2.6%; at least 1 antibody positive- 4.6% | | | | | | IDDM associated antibodies and thyroid antibodies were significantly more frequent both in recent-onset IDDM group and first-degree relatives, compared to controls (p<0.05); the relevance of IgG/IgA AGA and IgA tTG was significantly higher in the group of recent-onset IDDM compared to first degree relatives and controls (p<0.05), but the difference between first-degree relatives and controls did not reach statistical significance; the overall frequency of GPC and adrenal antibodies did not differ significantly among the groups; as for coexistence of antibodies, recent-onset IDDM pts presented with 27% of the subjects testing antibody-positive-specific for 2 or more the envisaged disorders compared with 3.1% in the group of first-degree relatives and 0% of control population (p<0.05); recent-onset IDDM (n=197): IDDM-associated antibodies: ICA 82.1%; anti-GADA - 76.0%; anti-IA-2 antibodies - 44.4%; IAA - 37.8%; at lease 1 antibody - 93.4%; Thyroid disease-associated antibodies: anti-TPO+-TG antibodies - 18.4%; pernicious anemia-associated antibodies: anti-GPC - 5.6%; adrenalitis-associated antibodies: anti-adrenal cortex antibodies - 1.0%; first-degree relatives (n=882): IDDM-associated antibodies: ICA 4.9%; anti-GADA - 7.6%; anti-IA-2 antibodies - 4.0%; IAA - 3.4%; at lease 1 antibody - 11.6%; Thyroid disease-associated antibodies: anti-TPO+-TG antibodies - 7.8%; pernicious anemia-associated antibodies: anti-GPC -6.0%; adrenalitis-associated antibodies: anti-adrenal cortex antibodies - 1.1%; healthy control subjects (n=150): IDDM-associated antibodies: ICA 1.3%; anti-GADA - 2.6%; anti-IA-2 antibodies - 0.6%; IAA - 0.6%; at lease 1 antibody - 4.0%; Thyroid disease-associated antibodies: anti-TPO+-TG antibodies - 3.2%; pernicious anemia-associated antibodies: anti-GPC -3.2%; adrenalitis-associated antibodies: anti-adrenal cortex antibodies - 0.7%
Duplicate: no | Journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 197 pts with a new onset of IDDM diagnosed according to WHO criteria; 882 first-degree relatives; 150 healthy controls without a family history of IDDM
| Test/methodology: | Demographics:
| IDDM-associated antibodies: islet cell antibodies (ICA) - detected by IF, insulin autoantibodies (IAA) - radioimmunoassay, anti-IA-2 antibodies, and anti-GAD65 antibodies (anti-GADA) - both radioligand binding; thyroid disease-associated antibodies: anti-thyroid peroxidase (anti-TPO) and anti-thyroglobulin (anti-TG) - both ELISA; pernicious anemia-associated antibodies: anti-gastric parietal cell antibodies (anti-GPC) - IF; adrenalitis-associated antibodies: anti-adrenal cortex antibodies - IF; celiac disease-associated antibodies: IgA AGA, IgG AGA, IgA-tTG - all ELISA | 197 pts with IDDM (age (y): median 16, range 5–27, 43% F); 882 first-degree relatives - 485 were parents (age (y): median 43, range 22–59), 382 siblings and 15 offspring of IDDM pts (age (y): median 16, range 2–41)
| Biopsy criteria/description: | Incidence:
| n/r
| Confirmatory test:
| none
| Checked IgA def.
| n/r
Johnston, 1998 UK | Publication type: | Ethnicity: | MONICA 1991: 0.82% [15 (2 with a CD prior to screening program and 13 - screening revealed CD pts) out of 1823] biopsy proven CD making a prevalence of 1:122 | MONICA 1983: the estimated prevalence for CD from this survey is 4/1206, or 1:301; if the 2 deceased subjects are included prevalence raises to 6/1206, or 1:201 | | | | | | | MONICA 1991 survey: comparing the untreated CD group with controls, there were no differences between symptom profile or laboratory parameters: attendances at their General Practitioners for diarrhea, fatigue, anemia or weight loss; MONICA 1983 survey: comparison of standardized mortality rates between serology-positive subjects and the general population showed no significant difference (4 deaths observed from cancer during a follow-up, compared to the 4.28% (95% CI 1.09, 10.24) expected cancer deaths, giving a relative risk of cancer deaths as 0.94 (95% CI 0.3, 2.4); 13 deaths in total observed during follow-up, compared to 14.11 (95% CI 6.92, 22.23) expected deaths, giving relative risk of all deaths as 0.92 (95% CI 0.5, 1.6)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 1) MONICA 1991 survey study: 89 subjects tested positive for CD serology taken from 1823 subjects randomly tested for CD (2 pts were excluded from further analysis because they had CD diagnosis prior to follow-up of the screening program, but included in the assessment of prevalence); 2) MONICA 1983 survey study: 72 CD pts out of 102 who consented to a follow-up of 11.2 y (range 11.3–11.9)
| Test/methodology: | Demographics:
| IgA AGA - ELISA, normal range of 0–99 (97.5th percentile); IgA EMA - IF on a ME, positive was taken at a titre of 1:5 | MONICA 1991: 89 subjects with positive CD serology; age (y): mean 50.9, range n/r, 49.4% F; age- and sex-matched 89 controls: age (y): mean 51.1, range n/r, 49.4% F
| Biopsy criteria/description: | MONICA 1983: 72 with a known CD; age (y): mean 58.1, range n/r, 53% F; no controls were included in this survey
| enteropathy consistent with CD was considered to include severe partial VA, sub-total or total VA | Incidence:
| Confirmatory test:
| biopsy; Watson-Crosby capsule; biopsy done in 51 out of 87 pts in MONICA 1991 survey pts and in 20 out of 72 pts in MONICA 1983 survey group
| Checked IgA def.
| n/r
Kolho, 1998 Finland | Publication type: | Ethnicity: | 11 out of 1,070 were positive for IgA EMA; 8 out of these 11 were found to have CD on biopsy, giving the prevalence of CD in this group 1:130 | | | | | | | | In 7 pts agreeing to start GFD, a 2nd biopsy done after 6 mos, revealed villous structural changes to normal in 6 pts and in 1 to subtotal atrophy
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | not at risk: 1,070 adults of Finnish ancestry screened for CD
| Test/methodology: | Demographics:
| EMA-IF HUC; methodology n/r | 1,070 adult population with no clinical signs of CD screened at Helsinki University General Hospital during 1996
| Biopsy criteria/description: | Incidence:
| capsule or endoscopic biopsy; ESPGAN criterias; CD3-positive T cell calculation (limit for high cell number was 77 cells/mm; limit for a moderate cell number was 63 cells/mm); gamma/delta T-cell receptor-bearing cell calculation (limit for a high cell number was 8.2 cells/mm)
| Confirmatory test:
| capsule or endoscopic biopsy
| Checked IgA def.
| n/r
Maki, 2003 Finland | Publication type: | Ethnicity: | Prevalence of CD was 1:99 (37/3654); prevalence of test positivity for CD was 56/3654; 10 of these were identified by symptoms, and of remaining 46, 27 had abnormal biopsy. all but two (52) of antibody pos pts had either HLA-DQ2 or the HLA-DQ8 haplotype; Prevalence of combination of antibody positivity and CD-associated HLA haplotype was 1 in 67 | | | | | | | | Unclear if 10 pts screened with serology were biopsied or not (abstract vs result table)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 3,654 schoolchildren
| Test/methodology: | Demographics:
| IgA-tTG, Celikey assay with low-cut off of 5U/mL; IgG-tTG, ELISA; IgA- and IgG-EMA, IF; total serum IgA - nephelometerical determination with serum levels of <0.05 g/L indicative of IgA deficiency; HLA- DR; DQ2 and DQ8 | asymptomatic schoolchildren median age: 12 y, range 7–16 y at the time of 1st sampling (1994)
| Biopsy criteria/description: | Incidence:
| endoscopic biopsy; the ratio of villous height and crypt depth less than 2 was considered to be indicative of CD
| Confirmatory test:
| biopsy in children with IgA EMA and IgA-tTG positivity (in 2001)
| Checked IgA def.
| yes
Mazzeti, 1992 Italy | Publication type: | Ethnicity: | By first AGA-IgA: 19 | | | | | | | | Not all systematically biopsied; only those with suggestive endoscopic features
| journal | n/r | biopsy proven: 18
Duplicate: no | Study design: | Patient type/# screened:
| cross-sectional prevalence | n=3,022; Roman school children
| Test/methodology: | Demographics:
| IgA-AGA; biopsy | age range: 13–15 y olds
| Biopsy criteria/description: | Incidence:
| atrophic or completely absent villi
| Confirmatory test:
| n/r
| Checked IgA def.
| n/r
Not, 1998, USA | Publication type: | Ethnicity: | Prevalence of test positivity: 4.8% (96/2000) for IgA and/or IgG; 0.4% (8/2000) for EMA | | | | | | | | No biopsy performed to diagnose CD; Confirmatory test: HLA DQA1& DQB1
Duplicate: no | journal | 1,740 Caucasians (87%), 230 African-American (11.5%), and 30 Asians (1.5%)
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 2,000 healthy blood donors
| Test/methodology: | Demographics:
| IgG and IgA-AGA - ELISA (goat immunoglobulin) cut-off was above mean ± 2 SD; IgA-EMA (IgA-AGA or IgG-AGA) - indirect IF on either ME or HU, cut-off n/r | mean age: 39 y
| Biopsy criteria/description: | % F: 48
| n/r | Incidence:
| Confirmatory test:
| no biopsy in the 96 IgA/IgG pos or 8 EMA positive pts; HLA haplotype typed in 4 EMA-positive and 23 EMA-negative donors; all 4 EMA-positives carried CD-associated alleles: 3 had DQA1*0501 and DQB1*0201 haplotype and 1 - DQA1*03 and DQB1*0302
| Checked IgA def.
| yes; none of 86 donors with positive IgG AGA and negative IgA AGA/EMA had IgA deficiency
Pittschieler, 1996 Italy | Publication type: | Ethnicity: | By first serology: 140
Duplicate: no | journal | 2,778 German; 1,837 Italian | By confirmation serology: 9
| Study design: | Patient type/# screened: | By biopsy: 9
| Cross-sectional prevalence | healthy consenting adults
| Test/methodology: | Demographics:
| IgA- & IgG-AGA; IgA-EMA; biopsy | n=4,615; median age (y) 36.6; range 18–82
| Biopsy criteria/description: | Incidence:
| partial or total VA
| Confirmatory test:
| ?
| Checked IgA def.
| n/r
Riestra, 2000 Spain | Publication type: | Ethnicity: | overall prevalence of CD was 2.6:1000; in two-step screening prevalence rate was 0.8:1000 (1/1170, 95% CI 0–55%); in one-step screening prevalence was 1.7:1000 (2/1170, 95% CI 0–6.9%); as for test positivity: IgA or IgG AGA was positive in 15% (174/1170); 1/174 confirmed with EMA and biopsy; 1 CD biopsy proven CD was confirmed even if AGA and EMA were negative; HLA-DQ2 allele was found in 2/3 new CD pts
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 1,170 randomly selected individuals from general population
| Test/methodology: | Demographics:
| IgG/IgA-AGA-ELISA; values above 25 (children) and 34 (adults) AU for IgA or above 46 (children) and 42 (adults) AU for IgG were considered positive; IgA-EMA, IF, sera manifesting fluorescence at a titre of at least 1:5 was considered positive; The study was conducted as a 1) two step (determination of IgA/IgG AGA, if positive measuring IgA-EMA); and a 2) one-step protocol (measuring IgA-EMA) | age (y): mean 44.9+-20.9; range 2–89; 55.3% F
| Biopsy criteria/description: | Incidence:
| endoscopic biopsy; Marsh
| Confirmatory test:
| EMA- indirect IF ME; titre≥1/5; biopsy in IgA and IgG pos/IgG AGA pos with IgA deficiency or isolated EMA positives; HLA DQ2
| Checked IgA def.
| yes; none were found to have IgA deficiency
Rostami, 1999 Netherlands | Publication type: | Ethnicity: | Prevalence of CD in a healthy donors was 1 in 330 (3/1000); as for the prevalence of test positivity: 3/1000 were positive for EMA; biopsy in all of these 3 confirmed CD: 2/3 Marsh IIIb; 1/3 Marsh II | | | | | | | | All 3 EMA positive pts with CD carried the known susceptibility alleles for CD - HLA-DQA1*0501 and HLA-DQB1*0201
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 1,000 healthy blood donors
| Test/methodology: | Demographics:
| IgA-EMA, IF; IgA- nephelometry; methodology n/r | n/r
| Biopsy criteria/description:
| EPSGAN; Marsh
| Confirmatory test:
| endoscopic biopsy; endoscopically guided capsule (Fujinon)
| Checked IgA def.
| yes; none were found to have IgA deficiency
Rutz, 2002 Switzerland | Publication type: | Ethnicity: | Prevalence of CD was 1 in 132 (0.75%; 11/1450); as for the prevalence of test positivity: 11/1450 EMA/tTG positive; 10/11 (1refusal) EMA/TTG/AGA/AGG positive (second level of screening); 9/10 (1 refusal) biopsied: 8/9 Marsh III | | | | | | | | Assessing prevalence of CD authors included 2 pts who were EMA and TTG positive but refused biopsy as well as 1 pts with positive tests and a normal mucosal histology, calling it latent CD; biopsy proven CD was diagnosed in 8 pts, but prevalence was calculated taking into account 11 pts
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 1,450 students
| Test/methodology: | Demographics:
| IgA-EMA, indirect IF on ME; IgA-tTG- ELISA with lower threshold value 0.2 g/L; IgG-AGA and IgA-AGA | age range 12–18 y; 871 (60.1%) F
| Biopsy criteria/description:
| Marsh criteria; endoscopic biopsy
| Confirmatory test:
| endoscopic biopsy
| Checked IgA def.
| yes (0/1450)
Sanders, 2003 UK | Publication type: | Ethnicity: | Prevalence of CD in primary care population was 1% (12/1200; 95% CI 0.4–1.3%); as for the prevalence of test positivity: 13.5% (162/1200) were antibody positives: 139 - IgG AGA positive, 10 - IgA AGA positive; 4 both IgA/IgG AGA positive, 3 - only EMA positive, 4 - EMA and IgG AGA positive; 2 all antibody positive; 23 pts were eligible for biopsy; out of 22 biopsies (1 pts refused) CD was confirmed in 12 pts | | | | | | | | In the whole group of 1,200 screened individuals there were 3 subgroups of pts suffering from: 1) IDA - n=64 (5.3%); 2) IBS - n=123 (10.25%); and 3) fatigue - n=92 (7.7%); prevalence of CD in IDA group was 4.7% (3/64, 95% CI 0–9.8%); prevalence of CD in IBS group was 3.3% (4/123, 95% CI 0.1–0.6%); prevalence of CD in the fatigue group was 3.3% (3/92, 95% CI 0–7%)
Duplicate: no | Journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 1,200 randomly selected individuals divided in 2 groups: visitors and pts: 1) 609 pts with a non CD-related symptoms in 338; 2) visitor group 591 individuals with a non-CD associated symptoms found in 409 (69.2%)
| Test/methodology: | Demographics:
| IgG and IgA - ELISA; EMA-indirect IF of ME; methodology n/r | 1) pts group: age (y): median 48, range 16–91; 64.4% F; 2) visitors group: age (y): median 45, range 18–85; 61.1% F
| Biopsy criteria/description: | Incidence:
| Revised Marsh
| Confirmatory test:
| biopsy
| Checked IgA def.
| yes
Sjoberg, 1994 Sweden | Publication type: | Ethnicity: | Prevalence of CD in blood donors was at least 1 in 1,500; as for test positivity: 22/1537 (1.43%) pts were positive for IgG and IgA AGA; 13 of these 22 pts were biopsied and 1 of 13 had biopsy confirmed CD | 12 y old children- 15/384 (3.9%) were positive for IgG and/or IgA AGA | 57 y old women- 11/944 (1.17%) were positive for IgG and/or IgA AGA; | | | | | | No biopsy results for IgA IgG positive school children and middle aged women was reported
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 1) 1,537 consecutive healthy blood donors; 2) 384 school children; 3) 944 women
| Test/methodology: | Demographics:
| IgG AGA- ELISA, cut-off 330; IgA AGA- cut-off 8.5; (arbitrary cut-off values adopted based on normal samples) | 1) age (y): mean 38, range 19–70; 27.3% F; 2) 12 y; 51% F; 3) 57 y women only
| Biopsy criteria/description: | Incidence:
| Marsh; Watson Capsules
| Confirmatory test:
| biopsy
| Checked IgA def.
| n/a
Sjoberg, 1999 Sweden | Publication type: | Ethnicity: | Positive results from 1970 pts IgG AGA- 60/1970 (3%) IgA AGA- 150/1970 (7.6%); both IgA and IgG- were 25/210 for a total of 185/1970 (9.4%) who had either IgA or IgG. Those 185 serum samples were analysed for EMA 3/185 positive 3 had small bowel Bx, 2 subtotal VA, 1- total VA. One had classic CD and 2 had infiltrative lesions and were on GFD with improvement. Thus prevalence rate for confirmed CD 4:1970 (0.20%) if infiltrative lesions regarded as CD prevalence 6:1970 (0.30%)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 1,970 blood donors
| Test/methodology: | Demographics:
| IgA-AGA, ELISA values above 8.5 arbitrary units were considered positive; IgG-AGA, ELISA values above 330 arbitrary units were considered positive; EMA, IF ME | 685 women 1,285 men (adults)
| Biopsy criteria/description: | mean age: 41.2 y, range 18–70 y
| subtotal and total VA considered diagnostic of CD. Infiltrative lesions, i.e., increased level of IELs were also considered as CD | % F: 35
| Confirmatory test: | Incidence:
| small bowel biopsy | Time period: between Oct. 1996-Feb.1997 (4 mos)
| Checked IgA def.
| n/r
Trevisol, 1999 Italy | Publication type: | Ethnicity: | By first serology: 10
Duplicate: no | journal | White Caucasians | By biopsy: 10
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | healthy adult blood donors
| Test/methodology: | Demographics:
| IgA-EMA; biopsy | n=4,000; mean age 35 y; range 18–60
| Biopsy criteria/description: | Incidence:
| subtotal or total VA
| Confirmatory test:
| ?
| Checked IgA def.
| n/r
Ventura, 2001 Italy | Publication type: | Ethnicity: | Overall at risk 18/240 were EMA positive and confirmed positive with intestinal biopsy (7.5%) | Stature growth defect 8:105 (7.6%) | Recurrent abdominal pain 3:45 (6.6%) | Sideropenic anemia 4:17 (23.5%) | Autoimmune disease 1:19 (5.2%) | Down syndrome 1:11 (9.0%) | CD first-degree relative 1:14 (7.1%)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 19,791 children visiting family pediatrician over a 2 y period. Inclusion criteria “at risk”: short stature; recurrent abdominal pain; IDA; enamel hypoplasia; recurrent aphthous stomatitis; autoimmune disease (such as IDDM, juvenile arthritis, autoimmune thyroiditis), occult hypertransaminasemia, IgA deficiency Down syndrome or CD in a first degree relative 240 met criteria; first-degree relatives of newly diagnosed CDs of this study (n=17?)
| Test/methodology: | Demographics:
| IgA-EMA , indirect IF using HU | 240 (103 male 43%) mean age 4.8 y
| Biopsy criteria/description: | Incidence:
| ESPGAN a single specimen from the duodenal junction with a Watson capsule | Time period: Oct. 31, 1995- Oct. 31, 1997
| Confirmatory test:
| intestinal biopsy
| Checked IgA def.
| yes
Volta, 2001 Italy | Publication type: | Ethnicity: | By EMA: 0.57% (20/3483); | | | | | | | | Prevalence of 0.57% (20/3483) if included three pts with normal villous but with increased IELs
Duplicate: no | journal | Northern Italians | by biopsy: 0.49% (17/3483)
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 3,483 general population
| Test/methodology: | Demographics:
| IgA-EMA-HU | n=3,483; 12–65 y, only 784 in 12–25 group
| Biopsy criteria/description: | Incidence:
| Roy-Choudhry; Subtotal villous strophy
| Confirmatory test:
| ?
| Checked IgA def.
| n/r
Weile, 2001 Denmark & Sweden | Publication type: | Ethnicity: | Denmark: by IgA-AGA 4% (61/1573), by EMA 0.25% (4/1573) | Sweden: by IgA-AGA 3.2% (60/1866), by EMA 0.27% (5/1866); by biopsy 0.27% (5/1866)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | blood donors
| Test/methodology: | Demographics:
| serum IgA; IgG-AGA; IgA-AGA, cut-off >40 units; EMA; in cases of IgA <0.07g/L, IgG-AGA was analyzed | Denmark: n=1,573 adults mean age: 41.4 y, range >18 y % F 40.9
| Biopsy criteria/description: | Sweden: n=1,866 adults
| n/a | mean age = 37.6 y, range >18 y
| Confirmatory test: | % F: 31.7
| biopsy in the Swedish sample only | Incidence:
| Checked IgA def.
| yes; prevalence in both population of blood donors was 0.3%
West, 2003 UK | Publication type: | Ethnicity: | EMA positive 87/7527 (1.2%); EMA pos and abnormal tTGA 77/87 (89%) | | | | | | | | In the whole group of 1,200 screened individuals there were 3 subgroups of pts suffering from :1) IDA, n=64 (5.3%); 2)IBS, n=123 (10.25%); and 3) fatigue, n=92 (7.7%); prevalence of CD in IDA group was 4.7% (3/64, 95% CI 0–9.8); prevalence of CD in IBS group was 3.3% (4/123, 95% CI 0.1–0.6); prevalence of CD in the fatigue group was 3.3% (3/92, 95% CI 0–7)
Duplicate: no | Journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 7,550 general practice unselected
| Test/methodology: | Demographics:
| IgA EMA, indirect IF on commercial ME using 1:10 dilution; tTGA, ELISA >3 U/mL considered positive | 7,527 adults aged 45–76 y not previously diagnosed with CD, mean age 59 y; 4,444 (59% F)
| Biopsy criteria/description: | Incidence:
| no biopsy done | Time interval: 1990-1995
| Confirmatory test:
| tTGA (no confirmatory test conducted i.e. biopsy)
| Checked IgA def.
| yes

### Prevalence of CD in Associated Clinical Conditions—Patients with Suspected CD

Evidence Table 5. Prevalence of CD in patients with suspected CD

Author, Year, Location | Study Design | Patient Characteristics | Prevalence | | | | | | | Comments
| | | Group 1 | Group 2 | Group 3 | Group 4 | Group 5 | Group 6 | Group 7
Agardh, 2001 Sweden | Publication type: | Ethnicity: | IDDM group: by AGA: 6.8% (11/162); by EMA: 4.9% (8/162); by biopsy: 3.7% (6/162); by IgA-tTG: 5.6% (9/162); by IgG-tTG: 6/162 (3.7%) | control group: by AGA: 8.7% (24/277); by EMA: 0% (0/277); by IgA-tTG: 0% (0/277); by IgG-tTG: 0% (0/277) | | | | | | Type 1 diabetics having either DQB1*02 or DQB1*0302 had higher IgA-tTG levels than those not having these alleles (p=0.023)
| journal | n/a
Duplicate: yes, Celiac 1 (Carlsson et al., Pediatrics 1999;103:1248) | Study design: | Patient type/# screened:
| retrospective cross-sectional prevalence | Group 1: IDDM (three were known and treated CD cases)
| Test/methodology: | Group 2: generally healthy subjects
| tTG; HLA DQB1; AGA ≥25 AU; EMA titres ≥1:5, biopsies | Demographics:
| Biopsy criteria/description: | IDDM group: (n=165) with CD: median age 7 y, age range=1–13 y; 64% F Without CD: median age=10 y, age range 2–19 y, 44% F control group: (n=277) age range 11–16 y, 53% F
| as described in Carlsson et al., 1999 (Pediatrics 103:1248) | Incidence:
| Confirmatory test: | n/a
| biopsy
| Checked IgA def.
| n/r
Annibale, 2003 Italy | Publication type: | Ethnicity: | 7/59 (11.9%) had positive anti-tTG antibodies titre; biopsy-confirmed: 8.5% (5/59) | | | | | | | 40/59 subjects tested positive for various tests including tTG for CD detection and progressed to have upper endoscopy with biopsy
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| prospective prevalence | IDA in premenopausal women
| Test/methodology: | Demographics:
| IgA-tTG, ELISA normal values were < 7UA/mL | n=59 premenopausal women; age range 22–54 y with IDA Hb<12g/dLF
| Biopsy criteria/description: | Incidence:
| Marsh | Time period: March-July 2000
| Confirmatory test:
| Biopsy, antral, gastric body, and duodenal biopsy collected
| Checked IgA def.
| n/r
Bardella 1991 Italy | Publication type: | Ethnicity: | 26
Duplicate: no | journal | n/r
| Study design: | Patient type/# screened:
| prevalence | suspected CD: iron-deficient, bowel disturbances, chronic intermittent diarrhea, severe malabsorption, tiredness and wt loss, mineral metabolism deficiencies, gluten-intolerance in childhood not further investigated
| Test/methodology: | Demographics:
| IgA-AGA | n=60; median age 28 (range 15–69); 41 F/19 M
| Biopsy criteria/description: | Incidence:
| n/r
| Confirmatory test:
| Checked IgA def.
Bardella 2001 Italy | Publication type: | Ethnicity: | 50% (40/80)
| journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | suspected CD, confirmed and treated CD pts (to be excluded), disease control group (to be excluded)
| Test/methodology: | Demographics:
| IgA-tTG >10 AU/mL using GP liver; AGA >12 AU/mL; indirect IF EMA titre>1:10; biopsy | n=80 suspected CD; adult; mean age 39 y; age range 17–79 y; 70% F
| Biopsy criteria/description: | Incidence:
| n/a? didn't mentioned the biopsy results, not used for case diagnosis
| Confirmatory test:
| none
| Checked IgA def.
| yes, one found
Bode 1993 Denmark | Publication type: | Ethnicity: | 14 cases (7.3%)
Duplicate: no | journal | n/r
| Study design: | Patient type/# screened:
| cross-sectional prevalence | suspected CD; all children
| Test/methodology: | Demographics:
| AGA, IgG, IgA | n=191; 74 F/117 M; median age: 2.75 y (range 0.33–15.5 y)
| Biopsy criteria/description: | Incidence:
| all biopsied
| Confirmatory test:
| all biopsied criteria not stated
| Checked IgA def.
| no
Carroccio, 2002 Italy | Publication type: | Ethnicity: | By GP-tTG: 18.8% (39/207); by h-tTG: 14.5% (30/207); by biopsy: 11.6% (24/207)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | adult pts with suspected CD
| Test/methodology: | Demographics:
| serum EMA; serum anti-GP-tTG; serum anti-human-tTG | n=207; adult; median age 42 y; age range 17–84 y; 52.3% F
| Biopsy criteria/description: | Incidence:
| ESPGAN? Three groups: normal, partial VA or subtotal/total VA; positive for CD if partial or total VA
| Confirmatory test:
| biopsy
| Checked IgA def.
| Yes, none found
Chan, 2001 Canada | Publication type: | Ethnicity: | GI group: 12% (9/77) | DM group: 75% (12/16)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 77 pediatric pts with suspected CD; 16 type I diabetes
| Test/methodology: | Demographics:
| GP-tTG; EMA; biopsy | n=93; mean age: n/r; range 2 mos to 18 y; % F: n/r
| Biopsy criteria/description: | Incidence:
| Carey capsule, or 4–6 duodenal biopsies at time of endoscopy; no grade provided, a diagnosed case=increased number of IELs with associated subtotal or total VA
| Confirmatory test:
| biopsy
| Checked IgA def.
| Yes, two found
Chartrand, 1997 Canada | Publication type: | Ethnicity: | 30 (17%); mean age 3.7 y (range 0.6–11.2); 17 F/13 M
Duplicate: no | journal | n/r
| Study design: | Patient type/# screened:
| prevalence | suspected CD; n=179
| Test/methodology: | Demographics:
| biopsy | all children; mean age 5.2 y, range 0.5–18.1 y
| Biopsy criteria/description: | Incidence:
| ESPGAN
| Confirmatory test:
| Checked IgA def.
Csizmadia 1999, Netherlands | Publication type: | Ethnicity: | 1.2% (75/6127) by IgA-EMA, 18/75 refused small bowel biopsy; 0.51% (31/75/6127) VA | | | | | | | 26/27 with VA had the allele HLA-DQ2; prevalence 1:198 in children 2–4 y
Duplicate: no | journal (research letter) | n/r
| Study design: | Patient type/# screened:
| cross-sectional Prevalence | 6,127 children between ages of 2–4 y general population
| Test/methodology: | Demographics:
| IgA-EMA (methodology n/r) | 6,127 pediatric pts between 2–4 y; gender:n/r
| Biopsy criteria/description: | Incidence:
| n/r | Time period: between May 1997-June, 1998
| Confirmatory test:
| Small bowel biopsy, subset of 27 had HLA typing for DQ2
| Checked IgA def.
| n/r
Day, 2000 New Zealand | Publication type: | Ethnicity: | 27/36 EMA+; 5/11 biopsy confirmed
Duplicate: no | journal | n/r
| Study design: | Patient type/# screened:
| cross-sectional prevalence | pediatric input or output; single center; suspected CD: failure to thrive, short stature, chronic GI symptoms; DM; histological findings of CD; 6 mos-15 y
| Test/methodology: | Demographics:
| IgA, IgG-AGA, EMA | mean age: 63 mos (range 6 mos-15 y); % M: 58
| Biopsy criteria/description: | Incidence:
| single pathologist, Marsh
| Confirmatory test:
| biopsy on EMA pos
| Checked IgA def.
| yes
Fasano, 2003 USA | Publication type: | Ethnicity: | 1) At risk: a) 1st deg relatives-205/4,508 (4.55%); children-54/1,294 (4.17%); adults-151/3,214 (4.70%); b) symptomatic adults 28/1,910 (1.47%); children: 53/1326 (4.00%)
Duplicate: no | journal | 94% White; 3% Black; 1.5% Hispanic, 1% Asian, 0.5% other | 2) Not at risk: 1/4,126 (0.75%); adults-27/2,845 (0.95%); children-4/1281(0.31%); biopsy in EMA+ Marsh I-0%; Marsh II-30/116 (25.9%); IIIa-46/116 (39.7%); IIIb-24/116 (20.7%); IIIc-16/116 (13.8%); HLA DQ2-76/98 (78%); DQ8-16/98 (16%); DQ2 and 8–6/98 (6%); all EMA pos were also tTG pos
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 9,019 at risk of CD; 4,126 not at risk
| Test/methodology: | Demographics:
| EMA-IF; ME or HU; positive at 1:10 ; all positive EMA tested with human tTG ELISA positive at 2 SD above mean of healthy controls; HLA DQ2 and DQ8 | at risk: symptoms of CD (1,326 children, 1,909 adults); CD associated disorders; 4,508 1st deg relatives; 1,275 2nd deg relatives;
| Biopsy criteria/description: | not at risk: 2,000 blood donors (mean age 39 y range 19–65 y); 1,119 school children (mean age 12.3 y, range 6–18 y); 1,007 adults and children for routine physical (mean age: 39 y and 13.7 y; range: 19–71 y, and 2–18 y, respectively)
| single pathologist, Marsh | Incidence:
| Confirmatory test:
| htTG; biopsy; also small subset 98 EMA positive and 114 EMA neg had HLA DQ2/8 tested
| Checked IgA def.
| n/r
Fitzpatrick 2001 Canada | Publication type: | Ethnicity: | The prevalence of IgA-EMA positivity in children with recurrent abdominal pain was 1 in 92 (1%, 95% CI 0–6) | The prevalence of IgA-EMA positivity in controls was 1 in 81 (1%, 95% CI 0–7)
Duplicate: no | journal | n/r
| Study design: | Patient type/# screened:
| cross-sectional prevalence; authors state that the study is a case-control (doubtful) | 92 pts with recurrent abdominal pain screened for EMA positivity; 81 healthy children also screened for EMA positivity
| Test/methodology: | Demographics:
| IgA-EMA-IF using ME; positive when characteristic fluorescence pattern was produced | 92 pts with recurrent abdominal pain; age: n/r; 62% F; 81 healthy controls; age: n/r; 42% F
| Biopsy criteria/description: | Incidence:
| not performed
| Confirmatory test:
| None
| Checked IgA def.
| n/r
Hill 2000 USA | Publication type: | Ethnicity: | Prevalence of CD in pts at risk was 1 in 57 (21/1200); prevalence of test positivity: 2.8% (34/1200) was both EMA and AGA positive; 26 of pts (19 EMA positive) underwent biopsy and 21 were diagnosed with CD | | | | | | | 15 pts out of 34 EMA positives refused biopsy; thus prevalence of biopsy proven CD in pts at risk was at least 1 in 57; if considered above mentioned 15 pts, prevalence of CD could have been 1 in 33 (36/1200)
Duplicate: no | journal | n/r
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 1,200 pediatric group of individuals at risk of CD; pts were assigned to one of 7 groups: 1) chronic diarrhea (n=182); 2) abdominal pain (n=316); 3) IDDM (n=81); 4) short stature (n=259); 5) failure to thrive (n=123); 6) miscellaneous (Down's syndrome, thyroiditis, anemia, unexplained elevation of liver enzymes) (n=47); 7) asymptomatic relatives (n=192)
| Test/methodology: | Demographics:
| IgA-EMA, IF on ME, methodology n/r; IgA and IgG-AGA, ELISA, methodology n/r | 1,200 pediatric group of individuals at risk of CD; age: mean n/r; range: 6 mos-20 y; % F n/r
| Biopsy criteria/description: | Incidence:
| Marsh
| Confirmatory test:
| biopsy
| Checked IgA def.
| yes
Hin 1999 UK | Publication type: | Ethnicity: | Prevalence of CD in pts at risk was 1 in 57 (21/1200); prevalence of test positivity: 2.8% (34/1200) was both EMA and AGA positive; 26 of pts (19 EMA positive) underwent biopsy and 21 were diagnosed with CD | | | | | | | 126 cases tested for anemia: 21 positive
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional Prevalence | entry criteria: IBS, anemia, histological findings of CD, malabsorption symptoms, diarrhea, fatigue, thyroid disease, DM, wt loss, short stature, failure to thrive, epilepsy, infertility, arthralgia, eczema; 1,000 screened
| Test/methodology: | Demographics:
| EMA (ME); biopsy of positives; IgA levels, IgG-AGA for IgA deficient | n=271 M, mean age: 49.9 y (range 17ndash;84); n=729 F, mean age: 45.2 y, range 6 mos-85 y); 5.3% <10 y, 3.1% aged 80–90 y; % F: 73
| Biopsy criteria/description: | Incidence:
| Crosby capsule, EGD distal duod in 2 cases | # New cases: 30 pts (8 M:22 F) +ve EMA and +ve biopsy Time period: 30/1 y Control popn: 7 /preceding 1 y in absence of case finding
| Confirmatory test:
| biopsy; 100% positive; IEL: 1/30; mild VA: 1/30; partial VA: 1/30; subtotal VA: 14/30; total VA: 13/30
| Checked IgA def.
| yes
Hoffenberg 2003 USA | Publication type: | Ethnicity: | | 40/987 tested positive for tTG; 19/40 met criteria for CD (10 with intestinal biopsy and 9 with persistent tTG autoantibody seropositivity) | | | | | | By the age of 5 y, the adjusted risk estimate of the frequency of evidence of CD in general Denver population is 0.9%(95% CI, 0.4–2.0) or 1 in 104 (1:49 to 1:221).
Duplicate: no | journal | non-Hispanic white 56%, Hispanic 30%, African-American 7%, Asian-American 2%, or biracial/other 5%
| Study design: | Patient type/# screened:
| prospective stratified cohort study | 987 infants with high-risk genotypes: HLA DR3–3; DR3/4, DQB1*0302; DR4, DQ8 DR5/7 (since 2000)
| Test/methodology: | Demographics:
| IgA tTG | 987 infants (tested over 5 y span) gender n/r
| Biopsy criteria/description: | Incidence:
| Marsh score of 2 (enlarged crypts and increased numbers of intraepithelial lymphocytes) or 3 (any degree of VA) was considered evidence of CD | Time period: newborns between Dec 1993-Sept 1999
| Confirmatory test:
| TG autoantibody seropositivity on two separate occasions at least 6 mos apart; biopsy
| Checked IgA def.
| yes
Hogberg, 2003 Sweden | Publication type: | Ethnicity: | 10/120 (8.3%) prevalence, 2 were diagnosed in the original study 20 y prior, 8 new cases from the present follow-up study group. (biopsy confirmed); serum results: IgA-AGA 8/120 pos; IgA-EMA 0.5% (6/120) pos; IgA-TGA 3.8% (4/104) pos (3 pts with positive biopsy were not tested for IgA TGA) | | | | | | | IgA deficient pt, IgG antibodies positive. Biopsy findings were in serologically positive relatives IgA-TGA was performed in sera of n=104 when access to assay became available 1 yr later.
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| longitudinal follow-up, incidence & prevalence | 120 first degree relatives of CD pts
| Test/methodology: | Demographics:
| IgA-AGA, ELISA cut-off for a positive outcome 42.5 units; IgA-EMA, indirect IF using ME, antibody titre defined as the highest serum dilution yielding positive fluorescence; IgA-TGA, commercially available ELISA, highest cut-off value for positive results >30 units. | n=56 parents (adults), mean age 53.6 y, range 43–78 y; n=44 siblings (ped and adult), mean age 27.4 y, range 15–49 y; n=20 offspring, mean age 6.5 y, range 1–16 y; gender n/r
| Biopsy criteria/description: | Incidence:
| revised ESPGAN. Grade 1 normal; Grade 2 mild; Grade 3 moderate, Grade 4 total VA | Time period: 20 y follow-up study. Original study period Sept 1975-Feb 1981
| Confirmatory test:
| Small bowel biopsy
| Checked IgA def.
| yes, 5 cases found
Pittschieler, 2003 Italy | Publication type: | Ethnicity: | 6.5% (6/92) confirmed CD by both serology & biopsy within a few months of CD diagnosis in one of their relatives. 5 total VA and 1 partial VA; over 2–5 y a further 5.8% (5/86) confirmed positive with both HUC EMA-IgA and biopsy 1 partial VA and 4 total VA; combined prevalence=12% (11/92); 11/11 were carriers of HLA DQ2/ heterodimers | | | | | | | all 11 were clinically silent for CD
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| prospective prevalence | 92 first-degree relatives of CD pts. Yearly testing over 12 y period
| Test/methodology: | Demographics:
| EMA, HUC examined by fluorescence. Absence of binding was considered a negative test; HLA typing was done exclusively once diagnosis of CD was confirmed (micro-lymphocytotoxic technique) | n=92 at risk (first-degree relatives; 18 offspring and 74 siblings); aged 2–18 y
| Biopsy criteria/description: | Incidence:
| Small intestinal biopsy of first jejunal loop. Ferraris Watson capsule. Normal values being <3.2 cells/mm γ/δ T-cell receptors by immuno-histology | Time period: 12 y time period Jan 1990-Dec 2001
| Confirmatory test:
| biopsy, HLA typing
| Checked IgA def.
| yes, none found
Thomas, 1992 England | Publication type: | Ethnicity: | 2/97 mild enteropathy; 1/38 moderate enteropathy; 27/34 severe enteropathy=7.9%
Duplicate: no | journal | n/r
| Study design: | Patient type/# screened:
| cross-sectional prevalence | pediatric pts presenting with chronic diarrhea
| Test/methodology: | Demographics:
| biopsy | n=381; 64% <2 y; 20% 2–5 y; 16% 5–15 y; % F: 41.5
| Biopsy criteria/description: | Incidence:
| normal histology; mild enteropathy; moderate enteropathy; severe enteropathy; response to GFD
| Confirmatory test:
| n/r
| Checked IgA def.
| yes
Tursi, 2003 Italy | Publication type: | Ethnicity: | CD diagnosed in 49/11 screened relatives (44.14%) prevalence; Prevalence AGA 36.73%; EMA 38.78% ; anti-tTG 44.89% | | | | | | | Prevalence of antibodies was higher in severe histological lesions (Marsh IIIb-c) than in not so severe lesions (Marsh I-IIIa). Note: prevalence of AGA was higher than that of EMA/anti-tTG in less severe histological lesions
Duplicate: no | journal | n/r
| Study design: | Patient type/# screened:
| Prevalence | 111 first-degree relatives of pts with CD
| Test/methodology: | Demographics:
| IgA IgG, ELISA lower limit of positivity of IgA 0.2 EU/mL and IgG 10.0 EU/mL; IgA-EMA, indirect IF on ME; IgA-tTG, ELISA using GP liver substrate, lower limit of positivity was 7 UA/mL | at risk n=111 first-degree relatives: mean age 28.7 y, range (10–65 y); 38 M, 73 F
| Biopsy criteria/description: | Incidence:
| Marsh criteria 6 biopsies from small bowel from the second part of duodenum. Marsh Type I -‘infiltrative’ lesions with >30 lymphocytes/100 epithelial cells; Type II- ‘infiltrative/hyperplastic’ lesions; Type III-'partial (sub)total VA; partial VA Marsh IIIa); subtotal VA Marsh IIIb); and total VA as Marsh IIIc) | n/r
| Confirmatory test:
| biopsy
| Checked IgA def.
| yes
van Mook, 2001 Netherlands | Publication type: | Ethnicity: | 2.9% (1/35) Marsh IIIc on both biopsy and endoscopy
Duplicate: no | journal | n/r
| Study design: | Patient type/# screened:
| retrospective prevalence | 35 pts with IDA, anaemia defined as Hb <8.0 mmol/L in men or < 7.4 mmol/L in women. Iron deficiency defined as a serum ferritin level ≤20 μg/L for men or ≤10 μg/L in women; or serum iron concentration ≤45 μg/dL with a transferrin saturation of 10% or less, or the absence of iron stores in bone marrow biopsy specimens.
| Test/methodology: | Demographics:
| EGD; upper digestive tract endoscopy in 10/35; duodenal biopsies taken in 15/35 | n=35 pts: median age 71 y, range 22–89 y; 22 F (63%) and 13 M (37%),
| Biopsy criteria/description: | Incidence:
| Marsh | n/r
| Confirmatory test:
| biopsy
| Checked IgA def.
| no
Ventura, 2001 Italy | Publication type: | Ethnicity: | Overall at risk 18/240 were EMA positive and confirmed positive with intestinal biopsy (7.5%); | Stature growth defect 8/105 (7.6%) | Recurrent abdominal pain 3/45 (6.6%) | Sideropenic anemia 4/17 (23.5%) | Autoimmune disease 1/19 (5.2%) | Down syndrome 1/11 (9.0%) | CD first degree relative 1/14 (7.1%)
Duplicate: no | journal | n/r
| Study design: | Patient type/# screened:
| cross-sectional Prevalence | 19,791 children visiting family pediatrician over a 2 y period. Inclusion criteria “at risk”: short stature; recurrent abdominal pain; IDA; enamel hypoplasia; recurrent aphthous stomatitis; autoimmune disease (such as IDDM, juvenile arthritis, autoimmune thyroiditis),occult hypertransaminasemia, IgA deficiency Down's syndrome or CD in a first degree relative; 240 met criteria; first-degree relatives of newly diagnosed CDs of this study (n=17?)
| Test/methodology: | Demographics:
| IgA EMA, indirect IF using HUC | n=240: mean age 4.8 y; 103 M (43%)
| Biopsy criteria/description: | Incidence:
| ESPGAN a single specimen from the duodenal junction with a Watson capsule | Time period: Oct. 31, 1995- Oct. 31, 1997
| Confirmatory test:
| intestinal biopsy
| Checked IgA def.
| yes

### Prevalence of CD in High-Risk Patients—Type I Diabetes

Evidence Table 6. Prevalence/incidence of CD in patients with diabetes

Author, Year, Location | Study Design | Patient Characteristics | Prevalence | | | Comments
| | | Group 1 | Group 2 | Group 3
Agardh, 2001 Sweden | Publication type: | Ethnicity: | IDDM group: by AGA: 6.8% (11/162); by EMA: 4.9% (8/162); by biopsy: 3.7% (6/162); by IgA-tTG: 5.6% (9/162); by IgG-tTG: 6/162 (3.7%) | Control group: by AGA: 8.7% (24/277); by EMA: 0% (0/277); by IgA-tTG: 0% (0/277); by IgG-tTG: 0% (0/277) | | Type 1 diabetics having either DQB1*02 or DQB1*0302 had higher IgA-tTG levels than those not having these alleles (p=0.023)
Duplicate: yes, Celiac 1 - Carlsson et al., Pediatrics 1999;103: 1248 | journal | n/a
| Study design: | Patient type/# screened:
| retrospective cross-sectional prevalence | 1. IDDM (3 were known and treated CD cases); 2. generally healthy subjects
| Test/methodology: | Demographics:
| tTG; HLA-DQB1; AGA≥25 AU; EMA titres≥ 1:5, biopsies | ped; 1. IDDM group (n=165)-with CD: median age 7 y, age range 1–13 y, 64% F; without CD: median age 10 y, age range 2–19 y, 44% F. 2. control group (n=277)- age range 11–16 y, 53% F
| Biopsy criteria/description: | Incidence:
| as described in Carlsson et al., 1999 Pediatrics 103:1248
| Confirmatory test:
| biopsy
| Checked IgA def.
| n/r
Arato, 2002 Hungary | Publication type: | Ethnicity: | By EMA: 11.7% (24/205); by biopsy: 8.3% (17/205) | | | Randomly selected subject pool, considered more representative of the population than in the other studies. No significant difference among EMA positive children with or without jejunal VA
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | type I diabetes
| Test/methodology: | Demographics:
| EMA, indirect IF; serum IgA measured to avoid false-negative IgA-EMA tests in cases of IgA deficiency (serum IgA<0.2g/L); jejunal biopsy using Crosby capsule for EMA positives; intraepithelial gamma/delta T-cells elevated if >7 cells/mm (95% CI) | n=205; randomly selected ped pts with IDDM; mean age 11.6 y; age range 2.0–17.0 y; 42.9% F
| Biopsy criteria/description: | Incidence:
| other: not described | n/a
| Confirmatory test:
| jejunal biopsy
| Checked IgA def.
| yes; none found
Bao, 1999 USA | Publication type: | Ethnicity: | By tTG only: 11.6% (98/847); by tTG & EMA: 5.8% (49/847); by biopsy: 1.8% (15/20/98/847) | | | Levels of tTG IgA and IgA-EMA were correlated: r=0.44, p=0.002. Prevalence of tTG was higher in diabetics with HLA DQ2 or DQ8.
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | type I diabetes
| Test/methodology: | Demographics:
| tTG (ELISA) >0.05=positive; IgA-EMA using indirect IF; HLA genotype DQ B1 typing of peripheral WBCs with PCR amplification and hybridization; DQ alpha-typing performed with ampliType; DQ2, DQ8 | n=847; children and adult; mean age 14.5 y; range 0.7–77.7 y; % F?
| Biopsy criteria/description: | Incidence:
| Other: not described | n/a
| Confirmatory test:
| *consent to biopsies in only 20 of the 98 tTG positives
| Checked IgA def.
| no, not mentioned
Barera, 1991 Italy | Publication type: | Ethnicity: | By first AGA-IgA: 30 | | | Levels of tTG IgA and IgA-EMA were correlated: r=0.44, p=0.002. Prevalence of tTG was higher in diabetics with HLA DQ2 or DQ8.
Duplicate: no | journal | n/a | Biopsy proven: 16
| Study design: | Patient type/# screened:
| Test/methodology: | type I diabetes
| AGA IgA then if negative, IgG AGA | Demographics:
| Biopsy criteria/description: | n=498; children
| subtotal VA | Incidence:
| Confirmatory test: | n/a
| none
| Checked IgA def.
Barera, 2002 Italy | Publication type: | Ethnicity: | By 1 EMA only: 5.5% (15/273); after second EMA: 3.7% (10/273); by biopsy: 3.3% (9/10/273); if add the 1 excluded case (because diagnosed CD before developed IDDM): 3.6% (10/274) | | | Levels of tTG IgA and IgA-EMA were correlated: r=0.44, p=0.002. Prevalence of tTG was higher in diabetics with HLA DQ2 or DQ8.
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| prospective cohort; 6 years follow-up [did not give incidence measures, only prevalence] | type I diabetes
| Test/methodology: | Demographics:
| EMA, indirect IF; serum IgA <0.05 g/L in the presence of normal IgG and IgM were regarded as selective IgA deficiency; duodenojejunal biopsy in >8 y children with positive EMA; upper endoscopy for younger children, mucosal histology | n=273; children; mean age 8.28 y, age range 0.6–18.7 y; 42.5% F
| Biopsy criteria/description: | Incidence:
| Marsh; three types of lesions: 1. Infiltrative lesion normal mucosa, 2. Hyperplastic lesion with enlarged crypts infiltrated by IELs, 3. Some degree of VA with inflammation and hyperplastic crypts; diagnosis considered positive with demonstration of type 2 or 3 lesion | n/a
| Confirmatory test:
| biopsy
| Checked IgA def.
| yes, 2 selective IgA deficiency
Calero, 1996 Spain | Publication type: | Ethnicity: | By first AGA-IgA: 12
Duplicate: no | journal | n/a | Biopsy proven :4
| Study design: | Patient type/# screened:
| Test/methodology: | type I diabetes
| IgA-AGA if positive on two occasions | Demographics:
| Biopsy criteria/description: | n=141; children
| subtotal VA | Incidence:
| Confirmatory test: | n/a
| none
| Checked IgA def.
Cronin, 1997 Ireland | Publication type: | Ethnicity: | By EMA: 7.9% (8/101)
Duplicate: no | journal | n/a | By biopsy: 5.0% (5/101)
| Study design: | Patient type/# screened:
| cross-sectional prevalence | IDDM pts
| Test/methodology: | Demographics:
| EMA; biopsy | n=101 diabetic pts and n=51 controls; adolescent and adult; age range for diabetic pt 15–59 y. Other info n/a
| Biopsy criteria/description: | Incidence:
| other: not mentioned | n/a
| Confirmatory test:
| biopsy
| Checked IgA def.
| no, not mentioned
De Block, 2001 Belgium | Publication type: | Ethnicity: | Prevalence of CD in 399 pts with IDDM was 0.75% (3/399); prevalence of test positivity: 1) ICA - 39% (157/399); GADA - 70% (278/399); IA2A - 44% (177/399); aTPO - 22% (87/399); PCA - 18% (73/399); AAA - 1% (5/399); IgA EMA - 2% (9/399) | | | IgA-EMA was detected in 2.3% of IDDM pts particularly in HLA-DQA1*0501-DQB1*0201 subjects
Duplicate: no | journal | all Caucasians
| Study design: | Patient type/# screened:
| Cross-sectional Prevalence] | 399 pts with IDDM screened for different autoimmune diseases (176 children <18 y; 223 adults)
| Test/methodology: | Demographics:
| islet cell antibodies (ICA) - IF, cut-off level was >12 JDF; antibodies to glutamic acid decarboxilase-65 (GADA) - radiobinding assay, cut-off level was >2.6% tracer bound GADA; tyrosine phosphate antibodies (IA2A) - radiobinding assay, cut-off level was >0.5% tracer bound IA2A; thyroid peroxidase antibodies (aTPO) - radiobinding assay, cut-off was >100 U/mL; parietal cell antibodies (PCA) - IF, positivity at >1:20 dilution; antibodies to intrinsic factor (AIF) - radiobinding assay; anti-adrenal antibodies (AAA) - IF; anti-EMA - IF on a ME, positivity at >1:10 dilution; HLA DQ | 399 pts with IDDM screened for different autoimmune diseases; age (y): mean 26±16, range n/r; 53% F
| Biopsy criteria/description: | Incidence:
| no biopsy performed | n/a
| Confirmatory test:
| none
| Checked IgA def.
| n/r
De Vitis, 1996 Italy | Publication type: | Ethnicity: | By first IgA: 121 | | | 78/121 biopsied
Duplicate: no | journal | n/a | Biopsy proven: 63
| Study design: | Patient type/# screened:
| Test/methodology: | type I diabetes
| IgA, IgG then IgA EMA | Demographics:
| Biopsy criteria/description: | n=1,114; children & adults
| Marsh VA | Incidence:
| Confirmatory test: | n/a
| biopsy
| Checked IgA def.
Fasano, 2003 USA | Publication type: | Ethnicity: | 1) At risk - a) 1st deg relatives - 205/4,508 (4.55%); children - 54/1,294 (4.17%); adults - 151/3,214 (4.70%); b) symptomatic adults - 28/1,910 (1.47%); children - 53/1,326 (4.00%); 2) Not at risk - 1/4126 (0.75%); adults - 27/2,845 (0.95%); children - 4/1281(0.31%); biopsy in EMA pos - Marsh 1- 0%; 2 -30/116 (25.9%); 3a - 46/116 (39.7%); 3b - 24/116 (20.7%); 3c - 16/116 (13.8%); HLA DQ2-76/98 (78%); DQ8 - 16/98 (16%); DQ2 and 8 - 6/98 (6%); all EMA pos were also tTG pos
Duplicate: no | journal | 94% White; 3% Black; 1.5% Hispanic, 1% Asian, 0.5% other
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 9,019 at risk of CD; 4,126 not at risk
| Test/methodology: | Demographics:
| EMA-IF; ME or HUC; positive at 1:10; all positive EMA tested with human tTG ELISA positive at 2 SD above mean of healthy controls; HLA DQ2 and DQ8 | at risk: symptoms of CD (1,326 children, 1,909 adults); CD associated disorders; 4,508 1st deg relatives; 1,275 2nd deg relatives; not at risk: 2,000 blood donors (mean age 39 y, range 19–65 y); 1,119 school children (mean age 12.3 y, range 6–18 y); 1,007 adults and children for routine physical (mean age 39 y, and 13.7 y, range 19–71 y and 2–18 y, respectively)
| Biopsy criteria/description: | Incidence:
| single pathologist, Marsh
| Confirmation test:
| htTG; biopsy; also small subset 98 EMA positive and 114 EMA neg had HLA DQ2/8 tested
| Checked IgA def.
| n/r
Frazer-Reynolds, 1998 Canada | Publication type: | Ethnicity: | Estimated prevalence of CD in 236 pts with IDDM was 5.1% (12/236; 95% CI 2.7–8.8); as for test positivity: none were IgA deficient; 19 pts were IgA EMA positive; 2 refused biopsy; of 17 pts with IgA EMA, 12 had CD on biopsy | Estimated prevalence of CD in 56 pts with suspected malabsorption was 9% (5/56); as for test positivity: 3 pts were EMA positive and all had biopsy proven CD; 3 pts were IgA deficient and EMA negative and 1 of them was found to have CD on biopsy; 1 of 50 IgA-sufficient and EMA negative pts had biopsy proven CD | | Sensitivity and specificity of IgA EMA for the detection of CD in all 73 biopsied pts (both IDDM and GI pts) were 88.2% (15/17; 95% CI 63.6–98.5), respectively; when the 3 IgA deficient pts were excluded, sensitivity increased to 93.7% (15/16; 95% CI 69.8–99.8) and specificity remained unchanged (49/54, or 90.7%; 95% CI 79.7–96.9)
Duplicate: no | journal | 94% white; 3% Black; 1.5% Hispanic, 1% Asian, 0.5% other:
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 236 pts with IDDM screened for CD; 56 pts who underwent intestinal biopsy for suspected malabsorption
| Test/methodology: | Demographics:
| IgA EMA - IF using ME, positive if staining at a dilution of 1:10; total serum IgA, measured using rate nephelometry | 236 pts with IDDM; age (y): mean n/r, range 1–18; 50% F; 56 pts with GI complaints; age (y): mean n/r, range n/r; 43% F
| Biopsy criteria/description: | Incidence:
| Carey capsule; Marsh criteria
| Confirmatory test:
| biopsy
| Checked IgA def.
| yes; none of IDDM pts had IgA deficiency; 3 pts in suspected malabsorption group were found to have IgA deficiency
Gillett, 2001 Canada | Publication type: | Ethnicity: | Prevalence of CD in IDDM pts was 7.7% (18/233); prevalence of test positivity: 8.2% (19/233) was both EMA and AGA positive and all were white; 18 of these 19 pts underwent biopsy (1 was previously diagnosed with CD and was not offered biopsy); CD was confirmed in 14 of these 18 pts
Duplicate: no | journal | 209 White, 12 East Indian, 7 Asian, 4 First Nation, 1 African
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 233 pts with IDDM screened for CD
| Test/methodology: | Demographics:
| IgA EMA, IF on HU, starting dilution 1:5; positive sample were tested at increased dilutions until fluorescence disappeared; IgA tTG, ELISA; reference range of 140 AU/mL or less was calculated to include 3 SD above the mean (99% confidence limit) | 233 pts with IDDM screened for CD; age (y): median 12.9, range 1.3–19.2; 46% F
| Biopsy criteria/description: | Incidence:
| endoscopic biopsy; ESPGAN criteria; 4 biopsy specimens from distal duodenum; elevated IEL count was defined as more than 40 IELs per 100 enterocytes
| Confirmatory test:
| biopsy
| Checked IgA def.
| yes; using Nor-Partigen Total IgA Kit; 1 pt was found to be IgA-deficient
Hansen, 2001 Denmark | Publication type: | Ethnicity: | Screening revealed 9 biopsy proven CD in the 104 pts with IDDM, giving a prevalence of CD 10.4% (95% CI 4.6–16.2%), (11/106 - 2 pts had CD prior to screening); as for test positivity: of 104 tested pts 7 had IgA AGA, 19 - IgG AGA, and 10 - IgA EMA+ IgA tTG; 9 out of 10 EMA+tTG positive pts underwent biopsy (1 refused) and were found all of them to have CD | Control: none had been diagnosed with CD; as for test positivity: 1 had IgA AGA, 9 - IgG AGA, none - EMA or tTG | | Screening revealed IDDM pts with CD were significantly younger than the group of IDDM without CD (p=0.017); IDDM+CD group also had an earlier onset of diabetes: median 3.2 y (range 0.7–9.3 y), compared with 7.4 y (range 1.3–16.6 y) in pts without CD (p=0.005); in pts with IDDM+CD the height standard deviation score (SDS) was significantly lower compared with diabetics without CD (p=0.019); no statistically significant difference with regards of weight SDS and body mass index SDS; thyroid antibodies were significantly more frequent in IDDM+CD (36% – 4/12), whereas 12/94 (13%) of IDDM without CD and 2/106 (2%) of controls had detectable thyroid antibodies (p=0.04)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 106 pts with IDDM screened for CD; 106 aged-, and sex-matched healthy controls
| Test/methodology: | Demographics:
| IgA AGA - ELISA, cut-off n/r; IgA EMA - IF on a ME; IgA tTG - ELISA; thyroid antibodies: thyroid peroxidase (TPO) and thyroglobulin (TG), using radioimmunoassay | 106 pts with IDDM screened for CD; 2 had been previously diagnosed with CD; age (y): median 12.8, range 2.3–18.2; 47% F; median duration of IDDM 4.8 y, range 0.2–13.3 y; 1 pt had a second-degree relative with CD; 106 aged-, and sex-matched healthy controls; age (y): median 12.9, range 1.3–18.3; 47% F; none had relatives with CD
| Biopsy criteria/description: | Incidence:
| endoscopic biopsy; CD was diagnosed when mucosa showed partial or total VA, crypt hyperplasia and IEL infiltration
| Confirmatory test:
| endoscopic biopsy
| Checked IgA def.
| yes; none was IgA deficient
Jager, 2001 Germany | Publication type: | Ethnicity: | Recent-onset IDDM (n=197): IgG AGA - 10.2%; IgA AGA - 7.6%; anti-tTG IgA - 9.7%; at least 1 antibody positive - 16.8% | First-degree relatives (n=882): IgG AGA - 5.6%; IgA AGA - 2.6%; anti-tTG IgA - 3.2%; at least 1 antibody positive- 7.3% | Healthy control subjects (n=150): IgG AGA - 3.2%; IgA AGA -2.0%; anti-tTG IgA - 2.6%; at least 1 antibody positive- 4.6%
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 197 pts with a new onset of IDDM diagnosed according to WHO criteria; 882 first-degree relatives; 150 healthy controls without a family history of IDDM;
| Test/methodology: | Demographics:
| DDM-associated antibodies: islet cell antibodies (ICA) - detected by IF, insulin autoantibodies (IAA) - radioimmunoassay, anti-IA-2 antibodies, and anti-GAD65 antibodies (anti-GADA) - both radioligand binding; thyroid disease-associated antibodies: anti-TPO and anti-TG - both ELISA; pernicious anemia-associated antibodies: anti-gastric parietal cell antibodies (anti-GPC) - IF; adrenalitis-associated antibodies: anti-adrenal cortex antibodies - IF; CD-associated antibodies: IgA AGA, IgG AGA, IgA-tTG - all ELISA | 197 pts with IDDM (age (y): median 16, range 5–27, 43% F); 882 first-degree relatives - 485 were parents (age (y): median 43, range 22–59), 382 siblings and 15 offsprings of IDDM pts (age (y): median 16, range 2–41)
| Biopsy criteria/description: | Incidence:
| n/r
| Confirmatory test:
| none
| Checked IgA def.
| n/r
Kaukinen, 1999 Finland | Publication type: | Ethnicity: | In total 7 (11%) out of 62 pts were diagnosed to have biopsy-proved CD; 6 (10%) were previously diagnosed with CD, and 1 (3.6%) of the 28 pts undergoing biopsy also was diagnosed with CD; EMA was positive in 1 (3.6%) pts with a newly diagnosed CD; IgA AGA - in 7 (25%), and IgG AGA - in 1 (3.6%); 14 of 26 subjects were HLA-DQ2 positive, in addition 4 had a celiac-type DQ8 haplotype; thus, 18 (69%) had celiac-type and 8 (31%) - a non-celiac genetic background; | | | IDDM - insulin dependent diabetes mellitus; ATD - autoimmune thyroid disorder (including autoimmune thyroiditis or Graves' disease); APECED - autoimmune polyendocrinopathy-candidosis-cetodermal dystrophy; 11% prevalence does not necessarily depict the true frequency of CD in pts with more than one autoimmune disorder; all 62 pts were treated in endocrinological clinic, which can lead to referral bias
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 62 adult pts with more than one autoimmune endocrinologic disorder
| Test/methodology: | Demographics:
| IgA EMA - IF, screening dilution of 1:5 was considered as a positive; IgA and IgG AGA - ELISA, for IgA AGA lower limit of positivity was 0.2 EU/mL and for IgG AGA - 10.0 EU/mL | 67% F); ATD+addison's disease - 4 (age (y): median 52, range 34–53; 50% F); APECED - 4 (age (y): median 26, range 17–51; 25% F); IDDM+alopecia areata - 3 (age (y): median 20, range 17–30; 67% F); ATD+alopecia areata - 3 (age (y): median 48, range 33–57; 100% F); ATD+addison's disease+alopecia areata - 1 (age (y): median 42; 0% F); IDDM+addison's disease - 1 (age (y): median 32; 100% F)
| Biopsy criteria/description: | Incidence:
| endoscopic biopsy; ESPGAN criteria; 7 forceps biopsy specimens; histological classification as 1) normal; 2) mild partial VA; 3) severe partial VA; 4) subtotal VA; 3 and 4 were considered as CD
| Confirmatory test:
| endoscopical biopsy; performed in 6 (10%) previously diagnosed CD and in 28 pts without the diagnosis of CD; (23 refused biopsy, 3 - lost to follow-up, 2 - died); HLA DR and HLA DQ alleles in a dilution of 1:1500 using PCR/RFLP method
| Checked IgA def.
| n/r
Kordonouri, 2000 Germany | Publication type: | Ethnicity: | 23 (4.4%) of the 520 pts with IDDM were found to be positive for IgA anti-tTG; 18 (3.5%) - for EMA; and 18 (3.5%) - for IgA AGA; prevalence of biopsy proven CD in the whole group of IDDM pts was at least 1.7% (9/520), because in 10 pts with increased IgA anti-tTG levels biopsy was not performed; all 9 pts with biopsy confirmed CD were positive for anti-tTG, and 8 - for EMA | | | Study demonstrates that elevated IgA anti-tTG, especially when present on more than one occasion, may be more sensitive than EMA for detecting a silent form of CD; while prevalence of positive IgA anti-tTG was 4.4%, the incomplete prospective histological assessment by biopsy precludes a final calculation of the prevalence of biopsy-proven CD in this pts group
Duplicate: no | Journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 520 pts with IDDM and no clinical signs of CD
| Test/methodology: | Demographics:
| IgA anti-tTG - ELISA antibody titers above 15 were considered positive; EMA - IF, fluorescence at 1:5 dilution was considered as a positive; IgA and IgG AGA - ELISA, for both methods a level above 35 AU were considered as a positive | 520 pts with IDDM; age (y): median 14.2, range 1.6–27.3; 47% F; medium duration of IDDM 4.0 y, range 0–23.6 y
| Biopsy criteria/description: | Incidence:
| endoscopical biopsy; Marsh criteria
| Confirmatory test:
| endoscopical biopsy; Marsh criteria (stated as a reference 9); done in 13 CD pts out of 23 suspected CD pts (7 lost to follow-up, 3 - refused biopsy); 9 were found to have biopsy proven CD; IEL per 100 enterocytes counted after immunohistochemical staining for CD8+ cells (normal values in children up to 26 IEL per 100 enterocytes)
| Checked IgA def.
| yes; 9 pts out of initial 529 had below normal IgA levels and were excluded from further analysis
Lampasona, 1999 Italy | Publication type: | Ethnicity: | Increased levels of TGCA were detected in 122 of 287 pts with IDDM (43%; CI 37–48%); of the pts 25 (9%; CI 6–13%) had raised levels of IgA TGCA and 121 (42%; CI 36–48%) - IgG TGCA; in 24 pts (8%; CI 5–12%) both IgA and IgG TGCA were found | In the NIDDM group 2 pts had low levels of IgG TGCA only; as for HLA typing, 34 had DR3/4 genotype, 41 - DR3/X, 38 - DR4/Y and 15 - DRX/Y; increased TGCA were found in 22 (65% CI 46–80%) with the DR3/4 genotype, 19 of those with DR4/Y (50%; CI 33–67%), 16 with DR3/X (39%; CI 24–55%) and in 3 with DRX/Y (20%; CI 4–48%) | | Almost 10% of pts have autoimmunity typical of CD and another 30% have low level TGCA antibody binding; this high prevalence suggests either involvement of the gut in the pathogenesis of IDDM or that transglutaminase is a secondary autoantigen resulting from beta-cell destruction
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional Prevalence | 287 pts with a new onset IDDM; 119 pts with NIDDM; 213 pediatric controls with no family history of diabetes
| Test/methodology: | Demographics:
| human tissue transglutaminase C - TGCA IgA and TGC IgG; the threshold for positivity was the upper first percentile of normal controls, respectively 0.9 AU for IgG TGCA and 0.3 for the IgA TGCA; typing of HLA for 128 pts with IDDM either using the standard microcytotoxicity test on lymphocytes isolated by immuno-magnetic beads or by sequence specific PCR on DNA extracted from blood mononuclear cells; subjects grouped as DR3/X, DR4/Y, DR3/4, or DRX/Y | 287 pts with IDDM; age (y): median 10, range 0.8–33; 41% F; 119 pts with NIDDM; age (y): median 65, range 42–87; 45% F; 213 controls; age (y): median 4.4, range 0.1–11.2; 49% F
| Biopsy criteria/description: | Incidence:
| endoscopical biopsy; Marsh criteria
| Confirmatory test:
| n/r
| Checked IgA def.
| n/r
Li Voon Chong, 2002 UK | Publication type: | Ethnicity: | 1) prevalence of known CD in 509 IDDM pts was 1.4% (7/509); 2 of these 7 pts later on developed AITD | 2) in the 38 pts with coexisting IDDM and AITD screening revealed 1 pts with increased IgA EMA, but normal IgA AGA levels; none were diagnosed with biopsy proven CD, making a prevalence of CD 0% in this group | 3) in the 112 pts with IDDM alone screening for CD revealed 2 pts with increased IgA EMA and normal IgA AGA, 1 of whom had biopsy confirmed CD, making a prevalence of CD in this group 0.9% | Undiagnosed CD in pts with both IDDM and AITD is not increased compared with pts with IDDM alone; because 2 of 7 pts with known CD subsequently developed hypothyroidism, authors suggest that pts with known CD and IDDM be annually screened for AITD
Duplicate: no | Journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 509 pts with IDDM assessed during 1998; treated autoimmune thyroid disease - AITD - present in 28 (5.5%); 7 (1.4%) out of 509 had known CD; 38 pts with coexisting IDDM and AITD, but without known CD studied during 1999; and 112 pts with IDDM alone and without known CD assessed during 1999
| Test/methodology: | Demographics:
| IgA EMA - IF; IgA AGA - ELISA; total serum IgA | age (y): mean 29.4, range 16–45; 41% F; 38pts with coexisting IDDM and AITD screened for CD: age (y): mean 35.6, range 17–53; 66% F; 112 pts with IDDM alone screened for CD: age (y): mean 30.6+-9, range 16–57; 43% F
| Biopsy criteria/description: | Incidence:
| n/r
| Confirmatory test:
| biopsy
| Checked IgA def.
| yes
Lorini, 1996 Italy | Publication type: | Ethnicity: | IDDM pts: 3.75% (5/133) | IDDM pts: 3.75% (5/133) | | At the diagnosis of IDDM IgA AGA were elevated in 32% (17/53), and during a follow-up it decreased within a normal limits in 13 pts; out of 32 pts with IgA AGA normal levels at the diagnosis of IDDM, 2 developed IgA AGA increased levels during a follow-up; in all pts with IgA AGA positivity during a follow-up, R1-ARA and EMA levels were also increased; high IgA AGA levels at the onset of IDDM are a transient abnormal immunological response and do not predict the occurrence of CD; they should not be considered a primary indication for performing a diagnostic intestinal biopsy unless R1-ARA and EMA are present too; HLA-Dr3 and/or DR4 were present in all 5 pts with AGA, R1-ARA and EMA positive
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 133 pts with IDDM; 45 age-matched, apparently normal controls
| Test/methodology: | Demographics:
| IgA and IgG AGA: ELISA; levels more than 2 SD were considered abnormal - for IgA >10 AU; for IgG - >7500 AU; R1-ARA: IF on rat kidney and liver; IgA EMA: IF on a distal ME; HLA-DR3, HLA-DR4, HLA-DR7 | 133 IDDM - age (y): mean 14.1, range 1.4–28.4; 47.3% F; 53 pts were considered at the onset of IDDM and 49 of them were also investigated for a 1–10 y follow-up; 45 aged-matched controls (CO); age: mean, range n/r
| Biopsy criteria/description: | Incidence:
| n/r
| Confirmatory test:
| intestinal biopsy in 6 pts with constantly elevated IgA AGA during a follow-up
| Checked IgA def.
| n/r
Not, 1998, USA | Publication type: | Ethnicity: | Prevalence of test positivity: 4.8% (96/2,000) for IgA and/or IgG; 0.4% (8/2,000) for EMA | | | No biopsy performed to diagnose CD; Confirmatory test: HLA DQA1& DQB1
Duplicate: no | journal | 1,740 Caucasians (87%), 230 African-American (11.5%), and 30 Asians (1.5%)
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 2,000 healthy blood donors
| Test/methodology: | Demographics:
| IgG and IgA-AGA - ELISA (goat immunoglobulin) cut-off was above mean ± 2 SD; IgA-EMA (IgA AGA or IgG AGA) - indirect IF on either ME or HU, cut-off n/r | mean age: 39 y % F: 48
| Biopsy criteria/description: | Incidence:
| n/r
| Confirmatory test:
| no biopsy in the 96 IgA/IgG pos or 8 EMA positive pts; HLA haplotype typed in 4 EMA-positive and 23 EMA-negative donors; all 4 EMA-positives carried CD-associated alleles: 3 had DQA1*0501 and DQB1*0201 haplotype and 1 - DQA1*03 and DQB1*0302
| Checked IgA def.
| yes; none of 86 donors with positive IgG AGA and negative IgA AGA/EMA had IgA deficiency
Page, 1994, UK | Publication type: | Ethnicity: | Prevalence of test positivity: IGA-AGA was positive in 4.1% (73/1785); 49 of these 73 pts were biopsied; CD was diagnosed in 13 of 49 biopsied pts; in 8 out of 1,765 pts IgA and 1 pt was diagnosed with CD; in general, prevalence of newly diagnosed CD was at least 0.78% (14/1785); the overall prevalence of CD in the whole group (4 pts were previously diagnosed with CD) was at least 1% (18/1789); 0.4% (8/2000) for EMA | | | Prevalence of CD in IDDM pts group was at least 1:50 compared with 1:340 in pts with NIDDM
| journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 1,785 diabetic pts (43% with IDDM and 57% with NIDDM)
| Test/methodology: | Demographics:
| IgA-AGA-in-house ELISA; titers of >90 U/L were considered abnormal | n/r
| Biopsy criteria/description: | Incidence:
| n/a
| Confirmatory test:
| Biopsy
| Checked IgA def.
| yes (8 pts had IgA deficiency and 1 was found to have CD )
Rensch, 1996 USA | Publication type: | Ethnicity: | By first EMA: 3
Duplicate: no | journal | n/a | Biopsy proven: 3
| Study design: | Patient type/# screened:
| Test/methodology: | type I diabetes
| EMA | Demographics:
| Biopsy criteria/description: | n=47; adults
| Loss of villous architecture, crypt hyperplasia, and increased IELs | Incidence:
| Confirmatory test: | n/a
| none
| Checked IgA def.
Roldan, 1998 Spain | Publication type: | Ethnicity: | By first IgA: 19 | | | Mixed group diagnosed by different means
Duplicate: no | journal | n/a | Biopsy proven: 7
| Study design: | Patient type/# screened:
| Test/methodology: | type I diabetes
| IgA, IgG AGA (and known cases, and some tested with EMA) | Demographics:
| Biopsy criteria/description: | n=117; children
| ESPGAN | Incidence:
| Confirmatory test: | n/a
| none
| Checked IgA def.
Rossi, 1993, USA | Publication type: | Ethnicity: | By first EMA: 10 | | | Only 3/10 biopsied
Duplicate: no | journal | Patient type/#; screened: | Biopsy proven: 3
| Study design: | type I diabetes
| Test/methodology: | Demographics:
| EMA | n=211; children
| Biopsy criteria/description: | Incidence:
| ESPGAN
| Confirmatory test:
| none
| Checked IgA def.
Sategna-Guidetti, 1994 Italy | Publication type: | Ethnicity: | Prevalence of test positivity: CD pts -145/151 (96%) EMA positive(1:50–1:>2000); sensitivity of IgA EMA was 96% | Prevalence of biopsy proven CD in IDDM group was at least 2.6% (10/383): 2 pts out of 12 IgA EMA positives refused biopsy; prevalence of IgA EMA positivity was 3% (12/383) | Controls- 0/437 EMA positive; specificity of IgA AGA was 100% | Prevalence of CD in IDDM pts group was at least 1:50 compared with 1:340 in pts with NIDDM
Duplicate: no | journal | n/a
| Study design: | Patient type/#; screened:
| Cross-sectional prevalence | 383 consecutive IDDM adults; 151 CD pts (as true positives) and 250 healthy and diseased controls (as true negatives) to assess IgA EMA test sensitivity and specificity
| Test/methodology: | Demographics:
| IgA EMA - IF ME | IDDM - age (y): mean 39, range 16–84; 43.9% F
| Biopsy criteria/description: | Incidence:
| Roy-Choudhury capsule from upper jejunum; criteria of Roy-Choudhury
| Confirmatory test:
| endoscopic biopsy and Roy-Choudhury capsule
| Checked IgA def.
| no
Saukkonen, 1996 Finland | Publication type: | Ethnicity: | Prevalence of CD in IDDM pts was at least 2.4% (19/776); prevalence of test positivity: at the diagnosis of IDDM and or at 24/36 months follow-up 76/775 positive for IgA-ARA and or IgA-AGA; 35 of these 76 pts were biopsied; in 17 of 35 pts biopsy confirmed CD was found; 2 pts out of 76 pts with a negative antibodies/symptomatic/ were diagnosed by biopsy; overall, 19/776 biopsy confirmed cases; 19/19 positive IgA-ARA; 14/18 genotyped for HLA DR positive for DR3 and 10 (56%) positive for DR4; DQB2 present in 17/18 (94%) | | | The observed prevalence of CD is an underestimate, because biopsy was not performed in 17 pts who screened positive for IgA ARA or AGA in the follow-up sample
Duplicte: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 776 IDDM children
| Test/methodology: | Demographics:
| gA- reticulin-indirect IF goat anti-human antiserum; IgA and IgG AGA - ELISA cut-off >30% of an intralaboratory standard (intra and inter-assay CV of 5.6% and 10.5% for IgA, and 6.9% and 16.1% - for IgG, respectively) | children less than 16 y
| Biopsy criteria/description: | Incidence:
| n/r
| Confirmatory test:
| Biopsy for all pts with abnormally high levels of antibodies but not for those with initially (diagnosis of IDDM) positive antibodies but negative at follow-up (6, 12, 18, 24 and 36 mos)
| Checked IgA def.
| no
Schober, 2000 Aistria | Publication type: | Ethnicity: | Overall prevalence of biopsy proven CD was 1.49% (6/403); as for prevalence of test positivity: 12 pts had increased IgA EMA; 11 of these 12 were biopsied (1 refusal); on biopsy: 3 (0.74%) had Marsh I; 2 (0.49%) - Marsh 0; 1 - Marsh IIIa/c and 5 Marsh IIIc (1.49%)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 403 children and adolescents with type I diabetes
| Test/methodology: | Demographics:
| EMA - indirect IF of ME, any positive reading at a dilution of 1:10 was considered as a positive; IgG-AGA and IgA-AGA - ELISA; cut-off for IgG AGA was ->30 AU; for IgA-AGA - >25 AU | age (y): mean 12.4, range 1–22; 47.9% F
| Biopsy criteria/description: | Incidence:
| Modified Marsh and Crowe; Watson-type capsule
| Confirmatory test:
| Biopsy
| Checked IgA def.
| yes
Sigurs, 1993 Sweden | Publication type: | Ethnicity: | Minimum prevalence of CD in IDDM pts was 4.6% (21/459); prevalence of newly diagnosed CD was 3.4% (15/436); as for prevalence of test positivity: 4.3% (19/436) were IgA AGA positive; 18 of these 19 pts were biopsied; minimum PPV for IgA ARA was 77% (13 of 17)
Duplicate: no | journal | n/r
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 436 children with IDDM
| Test/methodology: | Demographics:
| IgA- AGA - ELISA, cut off level at least 25 AU; IgA and IgG ARA - IF; titers equal to or diluted more than 1:5 were considered positive | age (y): mean 13.6+-4.1, range 2–21 y, 46.3% F
| Biopsy criteria/description: | Incidence:
| Watson Capsule
| Confirmatory test:
| Biopsy
| Checked IgA def.
| yes (3 cases)
Sjoberg, 1998 Germany | Publication type: | Ethnicity: | Prevalence of biopsy proven CD was 1.8% (15/848): 8 out of 848 were previously diagnosed with CD; as for prevalence of test positivity: 258/848 were positive for IgA and/or IgG-AGA; 22/258 were positive for EMA giving a prevalence of 2.6%; 7/20 were biopsy positive (14/20 potential CD:4 death; 3 refused biopsy) | NIDDM- 1/745 previously diagnosed CD; 1/745 EMA positive; prevalence in total 0.27% | Secondary diabetes group- 3/71 IgG-AGA positive; no EMA positives; no previously diagnosed CD; prevalence of CD was 0% | Pts with previously known CD had more symptoms, more deficiency states and more autoimmune diseases than those identified by screening (p<0.001); IDDM pts with a diabetes duration of 31–40 y were characterised by a higher prevalence of CD than pts with a duration of less than 30 y (6.7% vs. 1.7%; p<0.02)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 1,664 diabetes pts (848 IDDM; 745 NIDDM; 71 secondary diabetes)
| Test/methodology: | Demographics:
| IgA-AGA - ELISA, titre > 8.5 AU was considered positive; IgG-AGA - ELISA, titre > 330 AU was considered positive | IDDM - age (y): mean 46.1, range 17–86; 52.8% F; NIDDM - age (y): mean 61.7, range 24–92; 47.3 F; secondary diabetes - age (y): mean 53.9, range 33–77, 9.8% F
| Biopsy criteria/description: | Incidence:
| Marsh; Watson Capsule or gastroscopy and biopsy
| Confirmatory test:
| EMA-indirect IF of ME- titre ≥ 5; biopsy
| Checked IgA def.
| no
Spiekerkoetter, 2002 Germany | Publication type: | Ethnicity: | By IgA/IgG-tTG: 6.3% (13/205); by IgG-tTG: 5.4% (11/205); by biopsy 2.9% (6/8/13/205) [only 8 of the 13 with elevated tTGA levels agreed to biopsy]
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | ped IDDM pts
| Test/methodology: | Demographics:
| human tTG: IgA/IgG assay cut-off of 9.0 units, IgG-tTGA cut-off 7.0 units, IgA-tTGA cut-off 8.3 units | n=205; ped; median age=12 y 7 mos; age range=3–19.5 y; 47.3% F
| Biopsy criteria/description: | Incidence:
| Marsh
| Confirmatory test:
| biopsy
| Checked IgA def.
| no, not mentioned
Talal, 1997 USA | Publication type: | Ethnicity: | By EMA: 4.9% (9/185); by biopsy 2.2% (4/5/9/185) [only 5 of the 9 EMA positives underwent biopsy]
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | adult diabetic pts
| Test/methodology: | Demographics:
| EMA, cut-off at dilution ≥ 1:10; biopsy | n=185; adult; other info n/a
| Biopsy criteria/description: | Incidence:
| ESPGAN
| Confirmatory test:
| small bowel biopsy
| Checked IgA def.
| yes
Valerio, 2002 Italy | Publication type: | Ethnicity: | Type 1 diabetics 32/383 (8.3%); 2 out of 32 had IgA deficiency
Duplicate: Yes (see Celiac 1) | journal | n/a
| Study design: | Patient type/# screened:
| Prevalence | 383 type 1 diabetes pts
| Test/methodology: | Demographics:
| IgA AGA, ELISA; IgG AGA, ELISA; IgA EMA, indirect IF (substrate n/r) | 383 Type 1 diabetics (194 M, 189 F, 49% F) age < 18 y
| Biopsy criteria/description: | Incidence:
| ESPGAN | Time period: from January 1992 to December 2000
| Confirmatory test:
| small bowel biopsy
| Checked IgA def.
| yes
Vitoria, 1998 Spain | Publication type: | Ethnicity: | IDDM group: by AGA 17.2% (16/93); by EMA 7.25% (7/93); by biopsy 6.5% (6/93) | | | IDDM could develop in pts with silent, non-treated CD through gluten-mediated immune activation
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Prevalence | confirmed CD pts and IDDM pts; exclude confirmed CD pts for data extraction, irrelevant data
| Test/methodology: | Demographics:
| AGA; EMA; intestinal biopsy; IAA, GAD65, IA2, ICA tests to assess IDDM-related pancreatic autoimmunity among CD pts | 93 IDDM: pedi; mean age=10.5 y; ?% F
| Biopsy criteria/description: | Incidence:
| ESPGAN
| Confirmatory test:
| biopsy
| Checked IgA def.
| yes, none found

### Prevalence of CD in High-Risk Patients—Relatives

Evidence Table 7: Prevalence of CD in relatives of patients with CD

Author, Year, Location | Study Design | Patient Characteristics | Prevalence | | | | | | | Comments
| | | Group 1 | Group 2 | Group 3 | Group 4 | Group 5 | Group 6 | Group 7
Book, 2003 USA | Publication type: | Ethnicity: | Parents: 14.7% | Siblings: 21.3% | Offspring: 14.7% | Second-degree relatives: 19.5% | First cousins: 17.0% | | | HLA DQ available in 34/37 of the seropositives, all but one was DQ2 or DQ8
Duplicate: no | journal | n/a; but all families were Caucasian
| Study design: | Patient type/# screened:
| cross-sectional prevalence | Relatives of CD pts
| Test/methodology: | Demographics:
| IgA-EMA; tTG-ELIZA; HLA DQA1, DQB1 | n=163 first-degree relatives, n=82 second-degree relatives, n=47 first cousins; ped & adult; mean age=?; age range=2–78 y; % F?
| Biopsy criteria/description: | Incidence:
| n/a
| Confirmatory test:
| biopsy; diagnosis based on positive biopsy or had positive EMA and tTG serologies
| Checked IgA def.
| n/a
Corazza, 1997 Italy | Publication type: | Ethnicity: | 4%
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | Relatives of CD pts
| Test/methodology: | Demographics:
| AGA | n=328 first-degree relatives
| Biopsy criteria/description: | Incidence:
| Some VA
| Confirmatory test:
| n/a
| Checked IgA def.
| n/a
Farre, 1999 Spain | Publication type: | Ethnicity: | The prevalence of unrecognised CD in first-degree relatives of CD pts was 4.6% (31/669); the overall prevalence of CD in this group is 5.5% (37/675 - 6 relatives of CD pts were diagnosed with CD prior to the study); as for test positivity: IgA EMA was positive in 39/669 (5.8%) and IgA-AGA - in 13/669 (1.9%) relatives; simultaneous positivity occurred in 12 of 669 relatives (1.8%); of 39 EMA-positive relatives, biopsy has been done in 32 pts (7 refused) and CD were found in 31 individuals | | | | | | | HLA-DQ2 was typed in 12 of the 32 EMA-positive relatives who underwent biopsy and was positive in all cases; HLA-DQ2 haplotype was also present in 64% (108/169) of relatives, 93% (56/60) CD pts and 18% (9/50) of controls; all unrecognised CD relatives detected by screening were DQ2 positive
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 675 first-degree relatives in 227 families of CD probands (149 pediatric and 78 adult pts)
| Test/methodology: | Demographics:
| IgA EMA - IF either on a ME (n=550), or HU (n=119); positive ab 1:5 dilution and characteristic honeycomb staining pattern; IgA AGA - ELISA; values over 40 AU were considered positive; HLA-DQ2 (DQA1*0501 and DQB1*0201 alleles) were assayed in 169 pts; typing performed by PCR amplification | 669 first-degree relatives in 227 families of CD probands (149 pediatric and 78 adult pts) screened for CD (6 were diagnosed with CD prior to screening and excluded from the study, but accounted for overall prevalence); out of 669 relatives: 331 were parents (163 fathers, 168 mothers), 260 siblings (123 brothers and 137 sisters), and 78 children (42 sons and 36 daughters)
| Biopsy criteria/description: | Incidence:
| Watson-Crosby capsule; classification: 1) total VA; 2) severe partial VA with crypt hyperplasia; 3) minor non-specific abnormalities; 4) morphologically normal; 1 and 2 were diagnostic criterias for CD
| Confirmatory test:
| Watson-Crosby capsule; HLA-DQ2 typing performed in 169 first-degree relatives of CD pts, in 60 CD pts and in 50 ethnically matched controls from the general population
| Checked IgA def.
| yes, results were not explicitly given in the text. Presumably there was no case of IgA deficiency found because the alternative IgG test for such pts were not used or mentioned in the results section
Fasano, 2003 USA | Publication type: | Ethnicity: | 1) At risk - a) 1st deg relatives - 205/4,508 (4.55%); children - 54/1,294 (4.17%); adults - 151/3,214 (4.70%); b)symptomatic adults - 28/1,910 (1.47%); children - 53/1,326 (4.00%); 2) Not at risk - 1/4126 (0.75%); adults - 27/2,845 (0.95%); children - 4/1,281(0.31%); biopsy in EMA pos - Marsh 1- 0%; 2 -30/116 (25.9%); 3a - 46/116 (39.7%); 3b - 24/116 (20.7%); 3c - 16/116 (13.8%); HLA DQ2-76/98 (78%); DQ8 - 16/98 (16%); DQ2 and 8 - 6/98 (6%); all EMA pos were also tTG pos
Duplicate: no | journal | 94% white; 3% black; 1.5% Hispanic, 1% Asian, 0.5% other
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 9,019 at risk of CD; 4,126 not at risk
| Test/methodology: | Demographics:
| EMA - IF; ME or HU; positive at 1:10; all positive EMA tested with human tTG ELISA positive at 2 SD above mean of healthy controls; HLA DQ2 and DQ8 | at risk - symptoms of celiac (1326 children, 1909 adults); CD associated disorders; 4,508 1st deg relatives; 1,275 2nd deg relatives; Not at risk – 2,000 blood donors (mean age 39 range 19–65); 1,119 school children (mean age 12.3, range 6–18); 1,007 adults and children for routine physical (mean age 39, and 13.7, range, 19–71, and 2–18)
| Biopsy criteria/description: | Incidence:
| single pathologist, Marsh
| Confirmatory test:
| htTG; biopsy; also small subset 98 EMA positive and 114 EMA neg had HLA DQ2/8 tested
| Checked IgA def.
| n/a
Hill 2000 USA | Publication type: | Ethnicity: | Prevalence of CD in pts at risk was 1 in 57 (21/1200); prevalence of test positivity: 2.8% (34/1200) was both EMA and AGA positive; 26 of pts (19 EMA positive) underwent biopsy and 21 were diagnosed with CD | | | | | | | 15 pts out of 34 EMA positives refused biopsy; thus prevalence of biopsy proven CD in pts at risk was at least 1 in 57; if considered above mentioned 15 pts prevalence of CD could have been 1 in 33 (36/1200)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 1,200 pediatric group of individuals at risk of CD; pts were assigned to one of 7 groups: 1) chronic diarrhea (n=182); 2) abdominal pain (n=316); 3) IDDM (n=81); 4) short stature (n=259); 5) failure to thrive (n=123); 6) miscellaneous (down's syndrome, thyroiditis, anemia, unexplained elevation of liver enzymes) (n=47); 7) asymptomatic relatives (n=192)
| Test/methodology: | Demographics:
| IgA-EMA - IF on ME, methodology n/a; IgA and IgG-AGA - ELISA, methodology n/a | 1,200 pediatric group of individuals at risk of CD; age (y): mean n/a, range 6 mos - 20 y; % F n/a
| Biopsy criteria/description: | Incidence:
| Marsh
| Confirmatory test:
| Biopsy
| Checked IgA def.
| yes
Hogberg, 2003 Sweden | Publication type: | Ethnicity: | 10/120 (8.3%) prevalence, 2 were diagnosed in the original study 20 y prior, 8 new cases from the present follow-up study group. (biopsy confirmed); Serum results; IgA AGA 8/120 pos; IgA EMA 0.5% (6/120) pos; IgA TGA 3.8% (4/104) pos (3 pts with positive biopsy were not tested for IgA TGA) | | | | | | | IgA deficient pt, IgG antibodies positive. Biopsy findings were in serologically positive relatives IgA TGA was performed in sera of n=104 when access to assay became available 1 y later.
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| longitudinal follow-up, incidence & prevalence | 120 first degree relatives of CD pts
| Test/methodology: | Demographics:
| IgA-AGA, ELISA cut off for a positive outcome 42.5 units; IgA-EMA, indirect IF using ME the antibody titre was defined as the highest serum dilution yielding positive fluorescence; IgA-TGA, commercially available ELISA, highest cut-off value for positive results >30 units. | 56 parents (adults) mean age 53.6 range (43–78); 44 siblings (ped and adult) mean age 27.4 y age range (15–49); offspring 20 mean age 6.5 y age range (1–16). Gender not reported
| Biopsy criteria/description: | Incidence:
| revised ESPGAN. Grade 1 normal; Grade 2 mild; Grade 3 moderate, Grade 4 total VA | Time period: 20 y follow-up study. Original study period Sept. 1975- Feb. 1981
| Confirmatory test:
| Small bowel biospy
| Checked lgA def.
| yes, 5 cases found
Holm, 1993 Finland | Publication type: | Ethnicity: | 10.7%
Duplicate: no | journal | n/a
| Studu design: | Patient type/# screened:
| cross-sectional prevalence | Relatives of celiac pts
| Test/methodology: | Demographics:
| biopsy | n=121 first-degree relatives
| Biopsy | Incidence:
| criteria/description:
| Some VA
| Confirmatory test:
| n/a
| Checked IgA def.
| n/a
Korponay-Szabo, 1998 Hungary | Publication type: | Ethnicity: | Prevalence of CD in the whole screened population was 8.3% (83/997); prevalence for first-degree relatives in total: 8.6% (80/943) | parents: 4.2% (22/521) | siblings: 13.8% (51/368) | children: 12.9% (7/54); | second-degree relatives: 5.6% (3/54) | | | Screening revealed 75 new CD cases (in 71 IgA EMA were positive and in 4 - negative); 8 pts had been previously diagnosed with CD and were on a GFD and thus EMA negative; the total number of CD in the family members was 83; in 55 families two, in 10 families 3, in 1 family 4 and in 1 more family 6 members were affected by CD
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional Prevalence | 997 family members of 396 pts with CD screened for CD
| Test/methodology: | Demographics:
| IgA EMA - IF using ME and human duodenum as substrate; serum total IgA, deficiency was defined as total serum IgA<0.1 g/L | 997 family members of 396 pts with CD screened for CD (521 parents, 368 siblings, 54 children and 54 second-degree relatives); age: mean/median, range n/a
| Biopsy criteria/description: | Incidence:
| Watson capsule; histological evaluation according to the grading of Fontaine and Navarro; ESPGAN criteria for CD | # New cases: 75 new cases of CD; incidence of CD was 7.6% (75/989)
| Confirmatory test:
| biopsy; Watson-Crosby capsule; biopsy done in 77 out of 81 pts with positive IgA EMA
| Checked IgA def.
| yes; 2.1% (21/997) of all family members studied were IgA deficient; among CD diagnosed pts 10.8% (9/83) were IgA deficient
Kotze, 2001 Brazil | Publication type: | Ethnicity: | 3.5% | | | | | | | Negative serology, EMA litre = 1/5
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | Relatives of celiac pts
| Test/methodology: | Demographics:
| EMA | n=115 first-degree relatives
| Biopsy criteria/description: | Incidence:
| n/a
| Confirmatory test:
| n/a
| Checked IgA def.
| n/a
Mustalahti, 2002 Finland | Publication type: | Ethnicity: | Prevalence of CD in healthy, first-degree relatives of CD pts was 6.2% (29/466); as for test positivity: 72/466 pts (44 EMA pos 9.4% and 48 IgA pos 10.3%) were positive for EMA and IgA; IgA-tTG was positive in 12.9% (60/466) pts; IgA-EMA detected 97% of CD (28/29) and IgA-AGA detected - 51% (15/29); all 44 IgA EMA and 19/28 AGA positive pts were positive for DQ2; all 29 newly diagnosed CD pts were DQ2 positive | | | | | | | 15 pts out of 34 EMA positives refused biopsy; thus prevalence of biopsy proven CD in pts at risk was at least 1 in 57; if considered above mentioned 15 pts prevalence of CD could have been 1 in 33 (36/1,200)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional Prevalence | 466 healthy first-degree family members of CD pts
| Test/methodology: | Demographics:
| IgA-EMA- indirect IF on a HU, serum dilution of at least 1:5 was considered positive; IgA and IgG AGA - ELISA, level of AGA was considered positive when mean+-2 SD of healthy controls; IgA-tTG-ELISA, values at least 20 AU were considered positive | 466 healthy first-degree family members of CD pts; age (y): median 41, range 2–90
| Biopsy | Incidence:
| criteria/description:
| Small-bowel biopsies with pediatric or adult Watson capsule or forceps from the distal duodenum
| Confirmatory test:
| Biopsy; DQ2 and DQ8 typing on PCR
| Checked IgA def.
| n/a
Pittschieler, 2003 Italy | Publication type: | Ethnicity: | 6.5% (6/92) confirmed CD by both serology & biopsy within a few months of CD diagnosis in one of their relatives; 5 total VA and 1 partial VA; over 2–5 y a further 5.8% (5/86) confirmed positive with both HU EMA-IgA and biopsy 1 partial VA and 4 total VA; combined prevalence=12% (11/92); 11/11 were carriers of HLA DQ2/ heterodimers | | | | | | | All 11 were clinically silent for CD
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Prospective prevalence | 92 first-degree relatives of CD pts. Yearly testing over 12 y period
| Test/methodology: | Demographics:
| EMA, HUC examined by fluorescence. Absence of binding was considered a negative test; HLA typing was done exclusively once diagnosis of CD was confirmed =micro-lymphocytotoxic technique | 92 at risk (first-degree relatives; 18 offspring and 74 siblings); aged 2–18 y
| Biopsy criteria/description: | Incidence:
| Small intestinal biopsy of first jejunal loop. Ferraris Watson capsule. Normal values being less than 3.2 cells/mm γ/δ T-cell receptors by immunohistology | Time period: 12 y time period Jan 1990-Dec 2001
| Confirmatory test:
| biopsy, HLA typing
| Checked IgA def.
| yes, none found
Polvi, 1996 Finland | Publication type: | Ethnicity: | Prevalence of DQA1*0501 and DQB1*0201 positivity in CD index group: 100% (31/31) CD index pts were positive; relative risk for having at least two alleles 156 | Prevalence of DQA1*0501 and DQB1*0201 positivity in silent CD group: 100% (14/14) silent CDs | Prevalence of DQA1*0501 and DQB1*0201 positivity in siblings of index CD pts: 48% (14/29) healthy sibs | prevalence of DQA1*0501 + DQB1*0201 in cadaver organ donors: 28% (9/32) controls | | | | There was a very strong association of DRA1*0501 and DQB1*0201 alleles positivity with CD; the RR for an individual having at least 2 susceptibility alleles suffering from CD was as high as 156 (p<0.001); RR was also high (67; p<0.001) when the index cases were compared with their siblings. The etiologic fraction in both cases was 0.99
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional Prevalence | 31 CD index pts; 14 silent CD pts; 29 healthy siblings of CD index pts; 32 controls;
| Test/methodology: | Demographics:
| DQA1*0501 and DQB1*0201 | n/a
| Biopsy criteria/description: | Incidence:
| n/a
| Confirmatory test:
| n/a
| Checked IgA def.
| n/a
Robinson, 1971 UK | Publication type: | Ethnicity: | First-degree: 4.4% (3/68) | Second-degree: 0% (0/164) | Third-degree: 0% (0/238)
| journa | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | relatives of celiac pts
| Test/methodology: | Demographics:
| small bowel biopsy, Crosby capsule | 1) n=68, first-degree relatives=parents & siblings;
| Biopsy criteria/description: | 2) n=164, second-degree relatives=uncles & aunts, 50.6% F; 3) n=238, third-degree relatives=cousins, 52.1% F
| Other: normal, convoluted, and flat; either partial or subtotal VA represents confirmed CD | Incidence:
| Confirmatory test:
| biopsy
| Checked IgA def.
| n/a
Rolles, 1974 UK | Publication type: | Ethnicity: | 5.6%
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | Relatives of CD pts-CD child in family
| Test/methodology: | Demographics:
| biopsy | n=72 first-degree relatives
| Biopsy criteria/description: | Incidence:
| n/r
| Confirmatory test:
| n/a
| Checked IgA def.
| n/a
Rostami, 2000 Netherlands | Publication type: | Ethnicity: | Overall prevalence of CD in the first-degree relatives of CD pts was 11% (37/338); there were 17 new and 20 previously diagnosed CD cases; as for the prevalence of test positivity: 28% (96/338) were positive for clinical complaints + lab tests (4 pts) and serology screening; 17/96 (18%) biopsy positive; 6/17 Marsh IIIc; 5/17 Marsh IIIa; 6/17 strongly positive EMA and AGA
| journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | 388 first-degree relatives of CD pts
| Test/methodology: | Demographics:
| IgA-EMA- indirect IF on a primate ileum; min 1:5 and 1:100; IgA-AGA- ELISA, >25 AU/mL was considered positive; IgA by nephelometry | age (y): mean 39, range 1–80; 60% F
| Biopsy criteria/description: | Incidence:
| EPSGAN; Marsh 1992 | # New cases: 17 new cases of CD; incidence of 5% (17/338)
| Confirmatory test:
| biopsy in all pts with positivity of symptoms and/or serology tests
| Checked IgA def.
| yes; 3 individuals were found to have IgA deficiency
Stokes, 1976 UK | Publication type: | Ethnicity: | Fathers: 10.3% (4/39) | Mothers: 2.3% (1/43) | Brothers: 7.4% (5/68) | Sisters: 17.3% (13/75) | Sons: 8.3% (5/60) | Daughters: 17.1% (7/41) | 19.2% (35/182 total biopsied)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional Prevalence | Relatives of CD pts
| Test/methodology: | Demographics:
| biopsy | n=326; children and adult; other info n/a
| Biopsy criteria/description: | Incidence:
| biopsy result must be grade III to be considered confirmed CD: subtotal VA | # New cases: 17 new cases of CD; incidence of 5% (17/338)
| Confirmatory test:
| biopsy
| Checked IgA def.
| n/a; no serology done; not mentioned
Tursi, 2003 Italy | Publication type: | Ethnicity: | CD diagnosed in 49/11 screened relatives (44.14%) prevalence; prevalence AGA 36.73%; EMA 38.78% ; anti-tTG 44.89% | | | | | | | Prevalence of antibodies was higher in severe histological lesions (Marsh IIIb-c) than in not so severe lesions (Marsh I–IIIa). Noteworthy, prevalence of AGA was higher than that of EMA/anti-tTG in less severe histological lesions
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Prevalence | 111 first-degree relatives of pts with CD
| Test/methodology: | Demographics:
| IgA IgG AGA, ELISA lower limit of positivity of IgA 0.2 EU/mL and IgG 10.0 EU/mL; IgA EMA, indirect IF on ME; IgA tTG, ELISA using GP liver substrate lower limit of positivity of these antibodies was 7 UA/mL | at risk 111 first degree relatives 38 M, 73 F, mean age 28.7 y, range (10–65 y); 65.8% F
| Biopsy criteria/description: | Incidence:
| Marsh criteria 6 biopsies from small bowel from the second part of duodenum. Marsh Type I -‘infiltrative’ lesions with >30 lymphocytes/100 epithelial cells; Type II- ‘infiltrative/hyperplastic’ lesions; Type III-'partial (sub)total VA; partial VA Marsh IIIa); subtotal VA Marsh IIIb); and total VA as Marsh IIIc) | n/a
| Confirmatory test:
| Biopsy
| Checked IgA def.
| yes
Vitoria, 1994 Spain | Publication type: | Ethnicity: | Fathers: by IgA-AGA: 11.7% (21/180), by IgG-AGA: 13.9% (25/180), by EMA: 0% (0/180), by biopsy: 0.56% (1/180) | Mothers: by IgA-AGA: 9% (18/200), by IgG-AGA: 8.5% (17/200), by EMA: 2.5% (5/200), by biopsy: 2.5% (5/200)) | Brothers: by IgA-AGA: 8.3% (10/120), by IgG-AGA: 9.2% (11/120), by EMA: 3.3% (4/120), by biopsy: 2.5% (3/120) | Sisters: by IgA-AGA: 12.4% (16/129), by IgG-AGA: 15.5% (20/129), by EMA: 5.4% (7/129), by biopsy: 6.2% (8/129) | Offspring: by IgA-AGA: 15.4% (2/13), by IgG-AGA: 23.1% (3/13), by EMA: 7.7% (1/13), by biopsy: 7.7% (1/13)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional Prevalence | first degree relatives of celiac pts
| Test/methodology: | Demographics:
| IgA-AGA>0.085 AU in children, >0.128 AU in adults; IgG-AGA>0.45 AU in children, >0.317 AU in adults; EMA titre≥1:5 | n=642 (380 parents, 249 siblings, 13 offspring); ped and adult; mean age= 27 y; age range=1–64 y; 52.3% F
| Biopsy criteria/description: | Incidence:
| ESPGAN
| Confirmatory test:
| biopsy
| Checked IgA def.
| n/a

### Prevalence of CD in Associated Clinical Conditions—Anemia

Evidence Table 8. Prevalence of CD in patients with anemia

Author, Year, Location | Study Design | Patient Characteristics | Prevalence | | | Comments
| | | Group 1 | Group 2 | Group 3
Akerman, 1996 Israel | Publication type: | Ethnicity: | By biopsy: 13
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | out pts with IDA (50% symptomatic)
| Test/methodology: | Demographics:
| EGD/Biopsy | 93 pts; mostly adults although some teens
| Biopsy criteria/description: | Incidence:
| Subtotal or greater VA
| Confirmatory test:
| n/a
| Checked IgA def.
| n/a
Annibale, 2001 Italy | Publication type: | Ethnicity: | By biopsy: 6% (4/71); 71 pts formed the final sample of completely examined subjects. Note: no serology done | | | The celiac pts are younger compare to the rest of the sample
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | iron deficiency
| Test/methodology: | Demographics:
| antral (n=3 per pt)/body(n=3)/duodenal(n=2) biopsies; assessment of gastritis according to Sydney system; March classification for CD; colonoscopy for suspicious lesions; refusal of colonoscopy led to double-contrast barium enema; NOTE: no serology done | 81 pts; adult; median age 54; range 23–87; 74% F
| Biopsy criteria/description: | Incidence:
| n/a
| Confirmatory test:
| Biopsies
| Checked IgA def.
| no, not mentioned
Annibale, 2003 Italy | Publication type: | Ethnicity: | 7/59 (11.9%) had positive tTG antibodies titre; biopsy-confirmed: 8.5% (5/59) | | | 40/59 subjects tested positive for various tests including tTG for CD detection and progressed to have upper endoscopy with biopsy
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Prospective prevalence | IDA in premenopausal women
| Test/methodology: | Demographics:
| IgA tTG, ELISA normal values were <7 UA/mL | 59 premenopausal women age range 22–54 y with IDA Hb < 12g/dLF
| Biopsy criteria/description: | Incidence:
| Marsh | Time period: March-July 2000
| Confirmatory test:
| Biopsy - antral, gastric body, and duodenal biopsy collected
| Checked IgA def.
| n/a
Corazza, 1997 Republic of San Marino | Publication type: | Ethnicity: | By both EMA and biopsy: 1 in 559 pts, or 1.79 per 1000 [0.18%]
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| Cross-sectional prevalence | random sample stratified for age and sex
| Test/methodology: | Demographics:
| indirect IF EMA titre >1:5; biopsy | n=2,237; adult median age: 44 y; range: 20–87 y
| Biopsy criteria/description: | % F: 53.2
| n/a | Incidence:
| Confirmatory test:
| biopsy
| Checked IgA def.
| no, but mentioned as such that it could have caused some misclassification of pts, but the effect should be minimal given the powerful sensitivity and specificity of EMA test
Dickey, 1997 UK | Publication type: | Ethnicity: | prevalence of CD in IDA pts was 10% (4/41); EMA was positive in 3 (75%) of 4 these pts; prevalence of EMA and/or AGA being positive was 10% (4/41) | | | The celiac pts are younger compared to the rest of the sample
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 41 pts with IDA and no specific GI symptoms or evidence of a bleeding on FOBT or upper GI and colonic endoscopy screened for achlorhydric gastric atrophy and CD
| Test/methodology: | Demographics:
| EMA; AGA; methodology and cut-off levels n/a | 41 pts with IDA screened for achlorhydric gastric atrophy and CD; age (y): mean 59, range 15–84; 61% F
| Biopsy criteria/description: | Incidence:
| endoscopic biopsy; criteria n/a; finding of VA and IELs in duodenal biopsy
| Confirmatory test:
| Biopsy
| Checked IgA def.
| n/a
| | | Group 1 | Group 2 | Group 3
Howard, 2002 UK | Publication type: | Ethnicity: | By first serology: 28 y biopsy: 12 | | | 24/28 biopsied
Duplicate:no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | IDA identified through lab
| Test/methodology: | Demographics:
| IgA/IgG-AGA and EMA then biopsy | 258 adult pts with IDA, folate
| Biopsy criteria/description: | Incidence:
| n/a
| Confirmatory test:
| n/a
| Checked IgA def
| n/a
Kepczyk, 1995 USA | Publication type: | Ethnicity: | By biopsy: 4
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | Mostly symptomatic out pts with IDA
| Test/methodology: | Demographics:
| EGD/biopsy | 39 adult pts with IDA
| Biopsy criteria/description: | Incidence:
| VA, crypt hyperplasia, inflammatory infiltrate
| Confirmatory test:
| n/a
| Checked IgA def.
| n/a
McIntyre, 1993 UK | Publication type: | Ethnicity: | Prevalence of biopsy proven CD was at least 6% (3/50) | | | The celiac pts are younger compare to the rest of the sample
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 111 pts with IDA
| Test/methodology: | Demographics:
| duodenal biopsy performed in 50 pts; upper GI endoscopy performed in 108 pts | 111 pts with IDA; age (y): mean 63+-17.3, range 20–86; 61.3% F
| Biopsy criteria/description: | Incidence:
| n/a
| Confirmatory test:
| prevalence of biopsy proven CD was at least 6% (3/50)
| Checked IgA def.
| No serology tests done. Results based on clinical findings of upper & lower GI symptoms. Prevalence was calculated only in biopsy-performed group of pts that consisted of 50 individuals.
Oxentenko, 2002 USA | Publication type: | Ethnicity: | Prevalence of CD was 15% (17/113); 10 of these 17 pts had positive endoscopic markers suggestive of CD; 8 pts with endoscopic markers present did not have CD on biopsy | | | Only biopsy/no serology tests performed
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 113 pts with IDA
| Test/methodology: | Demographics:
| endoscopic biopsy of second and third parts of duodenum | age (y): mean 55.6+-15.3, median 54, range 20–86; 71.7% F
| Biopsy criteria/description: | Incidence:
| CD was defined as total or partial VA with IELs
| Confirmatory test:
| Biopsy
| Checked IgA def
| NA
Ransford, 2002 UK | Publication type: | Ethnicity: | Prevalence of newly diagnosed CD in anemic pts was at least 2.2% (11/484)prevalence of CD in “EMA positive pts” was 1 in 28; prevalence of CD in “definite celiac + ↑IELs alone+not biopsied group” was 1 in 30; prevalence of CD in “definite celiac and ↑IELs alone group” was 1 in 35; prevalence of CD in “definite celiac group” was 1 in 44 | Prevalence of newly diagnosed CD in age & sex matched non-anemic pts was 0.2% (1/484); prevalence of CD in “EMA positive group” was 1 in 83; prevalence of CD in “definite celiac +↑IELs alone+ not biopsied group” was 1 in 100; prevalence of CD in “definite celiac & ↑IELs alone group” was 1 in 166; prevalence of CD in “definite celiac group” was 1 in 498 | | Prevalence of newly diagnosed CD in anemic pts was at least 2.2% (11/484) compared with 0.2% (1/484) that of non-anemic pts (p<0.01)
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 484 anemic pts; 498 age and sex matched controls
| Test/methodology: | Demographics:
| IgA-EMA-ME, titers> 1:5 was considered positive; IgA tTG- ELISA, cut-off n/a | n/a
| Biopsy criteria/description: | Incidence:
| revised ESPGAN; duodenal histologic changes were graded according to Marsh criteria
| Confirmatory test:
| Biopsy
| Checked IgA def.
| No
Unsworth, 2000 UK | Publication type: | Ethnicity: | IgA EMA positive 32/483 (6.6%); 25/32 had small bowel biopsy (4 pts lost to follow-up and 3 refused further testing) 22/25 had positive small bowel biopsy(88%) | Prevalence of newly diagnosed CD in age & sex matched non-anemic pts was 0.2% (1/484); prevalence of CD in “EMA positive group” was 1 in 83; prevalence of CD in “definite celiac +↑IELs alone+ not biopsied group” was 1 in 100; prevalence of CD in “definite celiac & ↑IELs alone group” was 1 in 166; prevalence of CD in “definite celiac group” was 1 in 498 | | Prevalence of newly diagnosed CD in anemic pts was at least 2.2% (11/484) compared with 0.2% (1/484) that of non-anemic pts (p<0.01)
Duplicate: no | journal | n/a | Subsequent results 22/32 cases IgA AGA positive; 26/32 cases were either IgA or IgG AGA pos; 31/32 cases pos using ME as substrate rather than HU; 31/32 were IgA tTG antibody pos
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 110,937 blood donors, 1,380 anaemic donors, 483 with haemaglobin(<11 g/dL for women; <13.5 g/dL for men)
| Test/methodology: | 110,937 blood donors, 1,380 anaemic donors, 483 with haemaglobin (<11 g/dL for women; <13.5 g/dL for men)
| plasma diluted 1:5 IgA EMA using HU as substrate. Seropositives tested for IgA and IgG AGA ELISA and tTG ELISA using GP liver tTG | Demographics:
| Biopsy criteria/description: | 1,380 anemic adult blood donors 87% women (age range n/a) 483 anemic pts meeting criteria 84% women1
| n/a | Incidence:
| Confirmatory test:
| small bowel biopsy
| Checked IgA def.
| n/a
van Mook, 2001 Netherlands | Publication type: | Ethnicity: | 2.9% (1/35) Marsh III(C) on both biopsy and endoscopy
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| restrospective prevalence | 35 pts with IDA, anaemia defined as Hb below 8.0 mmol/L in men or below 7.4 mmol/L in women. Iron deficiency defined as a serum ferritin level equal to or below 20 ug/L for men equal to or below 10 ug/L ; or serum iron concentration equal to or below 45 ug/dl with a transferrin saturation of 10% or less, or the absence of iron stores in bone marrow biopsy specimens
| Test/methodology: | Demographics:
| EGD; upper digestive tract endoscopy in 10/35; duodenal biopsies taken in 15/35 | 35 pts, 22 F (63%) and 13 M (37%), median age 71 y range (22–89 y)
| Biopsy criteria/description: | Incidence:
| Marsh | n/a
| Confirmatory test:
| biopsy
| Checked IgA def.
| no

### Prevalence of CD in Associated Clinical Conditions—Low Bone Mineral Density (BMD)

Evidence Table 9. Prevalence of CD in patients with low BMD

Author, Year, Location | Study Design | Patient Characteristics | Prevalences | | | Comments
| | | Group 1 | Group 2 | Group 3
Gonzalez, 2002 Argentina | Publication type: | Ethnicity: | Prevalence of CD in 127 postmenopausal pts with osteoporosis was 1/127, or 7.9×1000 (95% CI 0.2–43.1); as for test positivity: AGA was found in 8 of 127 pts on level 1; 1 of these 8 pts was EMA-positive on the 2nd level and eligible for biopsy which established a diagnosis of CD | | | Prevalence of CD in postmenopausal osteoporotic women was similar to that of the general population
Duplicate: no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 127 consecutive postmenopausal pts with verified osteoporosis screened for CD; 747 controls screened for CD taken from a population-based study aiming to determine the prevalence of CD in Argentina
| Test/methodology: | Demographics:
| IgA and IgG-AGA, ELISA; cut-off levels: for IgA, 15 AU/mL; for IgG, 20 AU/mL; IgA-EMA, IF on ME; positive if fluorescence at 1:5 dilution; 1st level of screening: measuring of IgA and IgG-AGA; 2nd level of screening: measuring of IgA and IgG-EMA and total serum IgA if AGA positive; 3rd level of screening: biopsy in EMA positives | n=127 postmenopausal pts with osteoporosis; age: mean 68 y, range 50–82 y; n=747 controls; age: mean 29 y, range 16–79 y
| Biopsy criteria/description: | Incidence:
| endoscopic biopsy; CD was diagnosed when mucosa showed VA, crypt hyperplasia and intraepithelial lymphocytic infiltration (>30%) | [underlined: Time period]: prevalence of CD in 127 postmenopausal pts with osteoporosis was 1/127, or 7.9×1000 (95% CI 0.2–43.1); as for test positivity: AGA was found in 8 of 127 pts on level 1; 1 of these 8 pts was EMA-positive on the 2nd level and eligible for biopsy which established a diagnosis of CD
| Confirmatory test: | [underlined: Control popn]: estimated prevalence of CD in control women population was 6/747, or 8×1000 (95% CI 3.3–18.3); as for test positivity: AGA was found in 96 of 747 (12.8%) pts on level 1; 4 pts were EMA-positive and 2 other pts had very low serum IgA on the 2nd level and all 6 were eligible for biopsy which established a diagnosis of CD in all cases
| EMA: biospy
| Checked lgA def.
| yes; 2 controls were found to have very low IgA level
Lindh, 1992 Sweden | Publication type: | Ethnicity: | Prevalence of CD was 3% (3/92)
Duplicate : no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 92 consecutive pts with idiopathic osteoporosis screened for CD
| Test/methodology: | Demographics:
| IgA-AGA, micro ELISA method; cut-off point was selected to be a 2 SD above the mean in a healthy population of blood donors | n=92 consecutive pts with idiopathic osteoporosis screened for CD; 91% F (mean age 66±12 y)/ 9% M (mean age 50±12 y);
| Biopsy criteria/description: | Incidence:
| endoscopic biopsy; methodology and criteria of CD diagnosis n/r | prevalence of CD was 3% (3/92); IgA-AGA was positive in 11 of 92 pts and biopsy was performed in 6 pts
| Confirmatory test:
| endoscopic biopsy
| Checked IgA def.
| n/r
Mather, 2001 Canada | Publication type: | Ethnicity: | 7 (7.3%) of 96 pts were EMA pos at titers of ≥1:10; all biopsies were negative; prevalence of 0%
Duplicate : no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 96 consecutive idiopathic low BMD pts
| Test/methodology: | Demographics:
| IgA-EMA, IF of ME | n=96: mean age 57 y; range 18–86y; 81.3% (78) F, 18.7% M (18)
| Biopsy criteria/description:
| increased number of IELs with associated subtotal or total VA | Incidence:
| Confirmatory test: | n/a
| biopsy
| Chekced lgA def
| yes
Nuti, 2001 Italy | Publication type: | Ethnicity: | 53/255 pos IgG-AGA; 24/53 pos TG-ab (9.4%); intestinal biopsy in 10/24 resulted in 6 confirmed CDs
Duplicate : no | journal | n/a
| Study design: | Patient type/# screened:
| cross-sectional prevalence | 255 females with osteoporosis
| Test/methodology: | Demographics:
| lgA-AGA, ELISA cut-off level of 10U/mL-1 | mean age 66.6 y, range 36–65 y
| Biopsy criteria/description: | Incidence:
| intestinal biopsy criteria n/r | n/a
| Confirmatory test:
| TG-ab-ELISA with cut-off 22 AU; intestinal biopsy
| Checked IgA def.
| no

## Celiac 3: Risk of Lymphoma in CD

Evidence Table 10. Risk of lymphoma in patients with CD

Author, year, country | Methods | Participants | Outcomes | Measures of risk (lymphoma) | Measures of risk (mortality)
Askling, 2002, Sweden | Retrospective Cohort Study | CD pts: n = 11,019 | Lymphoma | SIR NHL 6.3 | SMR all causes 2
Other reports of same cohort | Study Dates: 1964-1994 | Mean age at CD Dx: 17.4 (range 0–>70) | # lymphomas 38 | 95% CI 4.2–125 | 95% CI 1.8–2.1
Peters et al., Arch Int Med 2003 ; 163:1566 | Group selection | Mean follow-up: 9.8 y (range 0–32) | Lymphoma types: NHLs | SIR 1–4 y Dx: 9.7 | SMR 1–4 y Dx: 2.2 (1.9–2.4)
| [underlined: Pts with CD]: All individuals discharged at least once with a Dx CD (ICD 7–9) | 97236 PYs | Dead patients | 95% CI 6.3–14 | SMR 5–9 y Dx: 2.0 (1.8–2.2)
| [underlined: Controls]: (5-y)Age/sex and (1 y) calendar period matched cancer incidence rate and mortality rate for the entire Swedish population | Proportion of females: 59% | Mean age at death: 68.6 | SIR >5 y Dx: 3.8 | SMR >10 y Dx: 1.7 (1.5–2.0)
| Institution: All hospitals in Sweden (Swedish input register) | Proportion on GFD: n/r | Time from CD Dx: n/r | 95% CI 2.2–6 | P(trend) 0.12
| Ascertainment of outcome | % refractory CD: n/r | Death from NHL | SIR age 0–59: 6.0 | SMR from NHL
| Cancer register, register of causes of death, population register, register of population changes. Pathology report from Cancer Registry for lymphomas Dx'ed 1990 or after | Clinical presentation: symptomatic (admission to hospital) | #Ls in celiacs: 33 | 95% CI 3.7–9.5 | 11.4 (7.8–16)
| Blinding | | # expected lymphomas:2.9 | SIR age >60: 5.8
| n/r | | Death from all causes | 95% CI 3.7–8.5
| Follow-up | | # deaths 828 | SIR childhood Dx (age 0–19): 1.9
| See ascertainment of outcome. 3.4% excluded with incomplete/non matching ID numbers | | # expected 419.3 | 95% CI 0.4–5.5
| | | Exclusions | SIR adult Dx (age 20–59): 7.7
| | | Were lymphomas occurring prior to CD Dx included? NO | 95% CI 4.9–12
| | | Were lymphomas occurring within 12 months of CD Dx included? NO | SIR late Dx (age >60): 6.3
| | | Were incidental lymphomas found at autopsy included? NO | 95% CI 3.8–9.8
| | | | SIR 1970-79: 12 (3.8–28)
| | | | SIR 1980-89: 8.5 (5.5–13)
| | | | SIR 1990-95: 3.4 (1.9–5.7)
| | | | P (linear trend) 1964-95 0.025
Collin, 1996, Finland | Prospective cohort study (Collin et al. Gut 1996;38:528) | CD pts: n = 383 | Lymphoma | SIR NH 2.66 | 10 and 15 y survival rates of pts with CD did not differ significantly from the rates seen in general population
Other reports of same cohort: | Study dates: 1970-1993 | Mean age at CD Dx: 41.8 (range 16–78) | # lymphomas 1 | 95% CI 0.07–14.8
Collin et al. Gut 1994; 35:1215 | Case-control study (Collin et al. Gut 1994;35:1215) | Mean follow-up: 8.1 y 3107 PYs | Lymphoma types:
| Group selection | Mean follow-up (case-control) 3.1 (range 0.511) | # expected lymphomas 0.4
| [underlined: Pts with CD]: All consecutive biopsy-proven CD (ESPGAN criteria) | Proportion of females: 73% | Death from all causes
| [underlined: Controls]: age/sex matched for Finnish population (database not stated) | Proportion on GFD: | # deaths: 31 (8.1%)
| [underlined: Controls(2):] age/sex and year matched outputs for upper endoscopy | Strict GFD 75% | # expected: see graph p1217 of Collin et al. Gut 1994;35:1215
| Institution: single tertiary care institution | Partial GFD 8% | Exclusions
| Ascertainment of outcome | Normal diet 6% | Were lymphomas occurring prior to CD Dx? NO
| Finnish cancer registry, Statistics Finland | Unknown 11% | Were lymphomas occurring within 12 months of CD Dx? YES
| Blinding | Compliance monitoring: control bx and dietary assessment 6–12 mos after Dx | Were incidental lymphomas found at autopsy included? PROBABLY NOT
| n/r | Clinical presentation:
| Follow-up | 82% symptomatic
| See ascertainment of outcome. 290 pts available for biopsy 6–12 mos post Dx | 18% serology Dx
Corrao, 2001 Italy | Prospective Cohort Study Dates: 1962-1994 | CD pts: n = 1,072 | Death from NHL | SIR NHL | SMR from NHL: 69.3
Other reports of same cohort: none | Group selection | Mean age at CD Dx: 35.7 (range 18–>50) | # lymphomas: 16 | | 95% CI 40.7–112.6
| [underlined: Pts with CD]: All consecutive biopsy-proven CD (ESPGAN criteria) | Median Dx delay 17 months | lymphoma types: # | | SMR all causes: 2.0
| [underlined: Controls]: (5-y) age/sex and calendar year matched national life tables and regional mortality rates | Mean follow-up: 6.0 y 6444 PYs | expected lymphomas 0.2 | | 95% CI 1.5–2.7
| Institution: 11 GI units throughout Italy selected for quality of record keeping; mostly tertiary | Proportion of females: 76% | Death from all causes | | SMR 0–3 y Dx: 0.98 (0.97–0.98)
| Ascertainment of outcome | Proportion on GFD: 59% | # deaths 53 | | SMR >3 y Dx: 0.98 (0.96–0.99)
| phone interview (pts, relatives); death certificates, Italian National Institute of Statistics | Strict GFD: 59% | # expected 25.9 | | SMR age 18–29 at Dx: 2.5 (0.5–7.3)
| Blinding | Not likely: 15% | Exclusions | | SMR age 30–49 at Dx: 2.4 (1.3–4.0)
| n/r | Unknown: 27% | Were lymphomas occurring prior to CD Dx included? NO | | SMR age >50 at Dx: 1.9 (1.3–2.6)
| Follow-up | Compliance monitoring: control biopsy and phone interview 1999 | Were lymphomas occurring within 12 months of CD Dx included? YES | | SMR 1962-74: 3.2 (1.4–6.3)
| see ascertainment of outcome. 8 pts or their relative not tracked down; excluded. 50 pts lost to follow-up | % refractory CD: none | Were incidental lymphomas found at autopsy included? PROBABLY NOT | | SMR 1975-84: 1.8 (1.0–3.1)
| | Clinical presentation: | | | SMR >1985: 2.0 (1.3–2.8)
| | 55% symptomatic | | | SMR Dx delay <1 y: 1.5 (0.9–2.3)
| | 39% mild symptoms | | | SMR Dx delay 1–10 y: 2.6 (1.6–4.1)
| | 6% serology Dx | | | SMR Dx delay >10 y: 3.8 (2.2–6.4)
| | | | | SMR symptoms: 2.5(1.8–3.4)
| | | | | SMR mild symptoms: 1.1 (0.5–2.2)
| | | | | SMR asymptomatic: 1.2 (0.1–7.0)
| | | | | SMR GFD: 0.5 (0.2–1.1)
| | | | | SMR unlikely: 6.0 (4.0–8.8)
| | | | | SMR uncertain: 2.0 (1.2–3.0)
Cottone, 1999, Sicily | Retrospective cohort study | CD pts: n = 228 | Lymphoma | SIR NHL 3.75 | SMR from NHL
Other reports of same cohort: none | Study dates: 1980-1997 | Mean age at CD Dx: 34.7 | #NHLs in celiacs: 7 | P<0.01 | n/r
| Group selection | adult Dx: 98% | Lymphoma types: ETCL (4), B-cell (2), other NHL(1) | | SMR all causes 3.8
| [underlined: CD pts]: All biopsy-proven CD | Range of age: n/r | # expected lymphomas: 1.824 | | 95% CI 1.9–6.7
| [underlined: Controls]: Age and sex-matched reported mortality from same period and region; cancer registry of the city of Ragusa in Sicily 1983-1987 | Mean follow-up: 73 mos (range 1–204) | % silent: n/r | | SMR 4 y from: 5.8
| Institution: Single institution; referral basis for all of Sicily | #PYs: n/r | % Dx'ed during childhood : 0 | | 95% CI 2.5–11.5
| Ascertainment of outcome | Proportion of females: 76% | Lymphoma patients
| Hospital medical records were reviewed; pathology specimen reviewed | Proportion on GFD: 100% | Mean age: 59.4
| Blinding | Compliance monitoring: serial EMA | Time from CD Dx: 78 mos
| n/r | % refractory CD: n/r | % compliant to diet: 100
| Follow up | Clinical presentation: | incidence NHL: 3%
| 5% incomplete records | Anemia 60% | expected incidence: 0.8
| | Malabsorbtion 20% | Death from lymphoma
| | Other 10% | # death from lymphoma in celiacs: 5
| | Asymptomatic 10% | # expected death from lymphomas: n/r
| | % inputs: 29% | Death from all causes
| | Marsh grade: n/r | # death CD: 12
| | | # expected deaths: 3.12
| | | # deaths within 4 y of Dx: 8
| | | # expected: 1.48
| | | Exclusions
| | | Were lymphomas occurring prior to Dx of CD included? NO
| | | Were lymphomas occurring within 6 months of CD Dx included? NO
| | | Were incidental lymphomas found at autopsy included? NO such cases
Delco, 1999 US | Case-control study | CD pts: n = 458 | Lymphoma | OR NHL 4.53
Other reports of same cohort: none | Study Dates: 1986-1995 | Controls: n=2692 | # lymphomas n/r | 95% CI 2.01–10.23
| Group selection | Mean age: | Lymphoma types: n/r
| [underlined: Pts with CD]: all consecutive pts discharged with CD Dx (ICD 579.0) | celiacs: 63.8 +/- 12.4 | # expected lymphomas n/r
| [underlined: Controls]: 5 randomly selected controls from same annual data file per case | controls: 59.7 +/- 14.8 p<0.0001 | Death from all causes
| Institution: All US VA hospitals | Proportion of females: | # deaths: n/r
| Ascertainment of outcome | celiacs 4% | Exclusions
| Pt Treatment File of the VA. Validity of records checked with 7 pt files | controls 2% p=0.105 | Were lymphomas occurring prior to CD Dx included? NO
| Blinding | Race: | Were lymphomas occurring within 12 mos of CD Dx included? LIKELY
| n/r | celiacs: 93% whites | Were incidental lymphomas found at autopsy included? LIKELY
| Follow-up | controls: 74% p<0.0001 | Pts with repeated admission within 1 y were excluded
| See ascertainment of outcome. | Proportion on GFD: n/r
| | Compliance monitoring: n/a
| | % refractory celiac: n/r
| | Clinical presentation:
| | 100% symptomatic (all discharged Dx)
Green, 2003,US (New York) | Prospective Cohort Study Dates: 1981-2000 | CD pts: n = 381 | NHL 1 mos after CD Dx | SIR NHL 6.2
Other reports of same cohort: none | Group selection | Mean age at CD Dx: 44 +/- 18 y | # lymphomas 5 | 95% CI 2.9–14
| [underlined: Pts with CD]: All consecutive biopsy-proven CD (ESPGAN criteria) | Duration of CD symptoms prior to Dx: 5y +/- 8 | # expected lymphomas n/r | SIR NHL before/1 mos after Dx celiac:*
| [underlined: Controls]: (5-y) age/sex and calendar year matched site-specific incidence rates from the National Cancer Institute's Surveillance, Epidemiology and End Results Program for whites | Mean follow-up: 6 +/- 11 y 1977 PYs | Age at Dx cancer 62+/- 8 y | 5.3 (2.3–13)
| Institution: single tertiary care institution | Proportion of females: 64% | Mean duration from celiac Dx 5+/- 4 y | incidence NHL 135/100 000 PYs
| Ascertainment of outcome | Proportion on GFD: 100% of NHLs after Dx | Mean follow-up 16+/- 17 y | expected 14.8/100 000 PYs
| pt interview, review of pathology records | Compliance monitoring: clinical interview, yearly AGA and EMA after 1993 | NHL before/1 mos after CD Dx* | SIR NHL any time before/after Dx celiac:*
| Blinding | % refractory celiac: n/r | # NHLs: 4 | 9.1 (4.7–13)
| n/r | Clinical presentation: n/r | # expected: 0.7
| Follow-up | | NHL any time before/after Dx celiac*
| pts not followed-up excluded; # n/r | | # NHLs: 9
| | | # expected: 1
| | | Lymphoma types:
| | | B-cell(3), T-cell (4 – ETCL 3), large cell (2)
| | | Exclusions
| | | Were lymphomas occurring prior to Dx of celiac included? YES*
| | | Were lymphomas occurring within 1 months of celiac Dx included? YES*
| | | Were incidental lymphomas found at autopsy included? n/r
| | | *separate analysis
Holmes, 1989, England | Prospective cohort study | CD pts: n = 210 | Lymphoma | SIR NHL 42.7
Other reports of same cohort: | Study Dates: 1941-1985 | Mean age at CD Dx: n/r | #NHLs in celiacs: 9 | 95% CI 19.6–81.4
Holmes et al. Gut 1976;17:612; Harris et al, Am J Med 1967;42:899 | Group selection | Adult Dx: 80%* (*from Harris et al, Am J Med 1967;42:899) | lymphoma types: n/r | SMR from NHL
| [underlined: Pts with CD]: All biopsy-proven CD | Mean follow-up: 17.4 PYs for men, 19.4 PYs for women; minimum 13 y | # expected lymphomas: 0.21 | n/r
| [underlined: Controls]: Age/sex matched incidence for 2 calendar periods standardized to ICD 8,200 and 202, in West Midlands region | Proportion of females: 55.2% | Lymphoma patients | SMR all causes
| Institution: Single institution | Proportion on GFD: 51% | Mean age: n/r | Not calculated
| Ascertainment of outcome | strict GFD 51% | Time from CD Dx: n/r | SMR 4 y from Dx
| Direct pt interview, case notes, GP, Birmingham and West Midlands cancer registry, autopsy results, death certificates, pathology specimen reviewed | reduced gluten 27% | % compliant to diet: | n/r
| Blinding | normal diet 22% | 2 NHL in strict GFD | SIR NHL
| n/r | Compliance monitoring: direct interview; repeat biopsy in 86 pts | 7 NHL in gluten diet | Strict gluten-free diet 44.4
| Follow-up | % refractory CD: 17 poor response to GFD | Death from lymphoma | Gluten diet 100
| Use of the family Practitioner Committee records and National Health Service Central Register at Southport; 2% drop outs | Clinical presentation: n/r | Not calculated
| | | Death from all causes
| | | Not calculated
| | | Exclusions
| | | Were lymphomas occurring prior to Dx of CD included? NO
| | | Were lymphomas occurring within 12 months of CD Dx included? NO
| | | Were incidental lymphomas found at autopsy included? No such cases
Logan, 1989, Scotland | Prospective cohort study | CD pts: n = 653 | Lymphoma | SIR NHL: n/r
Other reports of same cohort: | Study dates: 1979-1986 | Mean age at CD Dx: n/r | # lymphomas: n/r | SMR from lymphoma
Celiac 2; Logan et al. Gastroenterol 1986;90:334 | Group selection | Mean follow-up: 13.5 y 8823 PYs | Lymphoma types: most lymphosarcomas or reticulum-cell sarcomas, 2 Hodgkins | 31 p<0.001
Celiac 2; Logan et al. BMJ (Clinical research ed) 1983;286:95 | [underlined: Pts with CD]: All biopsy-proven CD entered in register for Edinburgh and the Lothians | Proportion of females: 60% | Dead patients | SMR(L) 0–1 y Dx: 108
| [underlined: Controls]: Age/sex matched mortality for Scotland and corresponding person-years over 5 calendar periods standardized to ICD 8 200–203, in Scotland | Proportion on GFD: n/r | Mean age at death: 60.8 | SMR(L) 2–4 y Dx: 9
| Institution: All hospitals in Edinburgh and the Lothian region, postal survey of all GPs, Scottish in-pt Statistics 1961-1977, local branch of Celiac Society | % refractory CD: n/r | Time from CD Dx: n/r | SMR (L) 5–49 y Dx: 22
| Ascertainment of outcome | Clinical presentation: n/r | Death from lymphoma | SMR all causes 1.9
| Death certificates | | #s in celiacs: 17 | 95% CI 1.5–2.2
| Blinding | | #expected lymphomas: 0.55 | SMR <1 y from Dx: 4.1
| n/r | | Death from all causes | SMR 1–2 y from Dx: 3.2
| Follow-up | | # deaths 115 | SMR 3–4 y from Dx: 2.2
| National Health Service Central Record, death certificates, Scottish national death records. | | # expected 61.8 | SMR 5–9 y from Dx: 1.5
| 6% lost to follow-up | | Exclusions | SMR 10–14 y from Dx: 1.5
| | | Were lymphomas occurring prior to CD Dx included? NO | SMR childhood Dx: 1.4
| | | Were lymphomas occurring within 12 months of CD Dx included? YES | 95% CI 0.4–3.7
| | | Were incidental lymphomas found at autopsy included? NO | SMR adult Dx: 1.9
| | | | 95% CI 1.5–2.3
| | | | SMR late Dx:* 1.7
| | | | 95% CI 0.02–4.8
| | | | *obvious CD symptoms during childhood
Selby, 1979 Australia | Retrospective cohort study dates: 1959-1978 | CD pts: n = 93 | Lymphomas | SIR NHL 4.94
Other reports of same cohort: none | Group selection | Mean age at diagnosis celiac: 40 (range 14–70) | # lymphomas 4 | p< 0.0005
| [underlined: Pts with CD]: All consecutive biopsy-proven CD (ESPGAN criteria) | Duration of Sx of celiac prior to Dx: 3yrs (range 2 wks to 26 y) | # expected lymphomas 0.081 | symptom duration (cancer vs none): not significant
| [underlined: Controls]: ?age/sex and period matched incidence New South Wales Central cancer Registry | Mean follow-up: 6 y (max 9 y) | Age at cancer Dx: 47.5 | age Dx (cancer vs none): not significant
| Institution: Single tertiary care institution | Proportion of females: 67% | Mean duration from CD symptoms: 11 y (range 2–26 y)
| Ascertainment of outcome | Proportion on GFD: 100% of NHLs after Dx | Mean follow-up: n/r
| direct call or via medical officer | Compliance monitoring: n/r | Lymphoma types: ETCL (2), lymphosarcoma (1), histiocytic medullary reticulosis (1)
| Blinding | % refractory CD: none of the lymphoma pts | Exclusions
| n/r | Clinical presentation: 100% malabsorption: 18% malabsorption during childhood | Were lymphomas occurring prior to Dx of celiac included? NO
| Follow-up | | Were lymphomas occurring concomitantly with celiac Dx included? NO
| Direct call or via medical officer. 21% lost to follow-up | | Were incidental lymphomas found at autopsy included? n/r

## Celiac 4: Consequences of Testing for CD

Evidence Table 11. Consequences of testing for CD

Study, Year Country | Methods | Participants | Outcomes | Results | Limitations
Addolorato, 2001 Italy | Study type - 1996- 1998 | Celiac - n=43 enrolled | Before/after GFD | Before - CD 71.4% showed high levels of state anxiety, 25.7% showed anxiety as a trait and 57.1% positive for depression compared to 23.7%, 15.2% and 9.6% of controls | Small sample, loss to 8 pts to follow-up
| Population-group selection | Controls - n=59 | Anxiety | Post GFD - 25.7% still affected by state anxiety, 17% trait anxiety, and 45.7% depressed | Relatively short follow-up
| Celiacs - newly diagnosed CD selected from outpatient clinic of 234 adult CD | Proportion F - 60% | State and Trait Anxiety | Significant decrease in state anxiety (p<0.001)
| Controls - healthy asymptomatic controls - matched for age, sex and SES | Mean follow-up - 1 y | Inventory test | No significant changes in trait anxiety or depression
| Loss to follow-up -8 Setting - Tertiary | Mean age: 29.8 ± 7.4 | Depression | - anxiety in CD predominantly reactive
| | | SDS self rating depression scale
Amin, 2002 UK | Study type - case controlled longitudinal | Celiacs: n=11 (6 had repeat small bowel Bx on GFD) | BMI | Cases: 1.1 ± 0.1 | Small sample
| 1994-1998 | Controls: n=22 | Hgba1c | Controls: 1 ± 0.1 | Selection of controls
| Population-group selection Celiacs - 11 pts, EMA + and biopsy diagnosed CD out of 230 pts screened from diabetic clinic | Age: 8.1 (1.2–16.1) cases, 7.4 (1.3–14.8) controls | Insulin regimens | Cases: 8.3 ± 0.2
| Controls - 22 matched for age, sex and duration of diabetes, with negative serology | Proportion of females: 54.5% | | Controls: 10 ± 0.2
| Institution - diabetic clinic - tertiary care hospital | Duration of type 1 diabetes: 4.2 y | | Insulin regimens increased but did not differ significantly between Insulin units 1.0
| | Mean follow-up - 4 y | | All reverted to antibody negative
| | BMISDS -1.2 ± 0.1 (SEM) vs -0.1 ± 0.1
| | WtSDS - 0.7 vs 0.5
| | HbgA1c - 8.3 cases
| | 9.8 controls
| | Insulin units - 0.8
Annibale 2001 Italy | Study type - prospective | Celiac n= 26 of 190 pts with IDA | Iron Deficiency (Hgb<14 for men and 12 for women, MCV <80, low serum iron and low serum ferritin | 6 mos 77.8% recovered IDA, but only 5 of 18 (27.8%) developed normal ferritin levels | Recovery from IDA occurs within the initial 6–12 mos but only 50% recover from iron deficiency
| 1994- May 1997 | Proportion F - 92% | Ferritin | 12 mos - 94.4% recovered from anemia and 50% from iron deficiency - all pts had normal RDW | In subgroup of pts (n=7) who had repeat biopsies at 6 and 12 mos - inverse correlation between histological grade and increase in Hgb
| Population-group selection | Mean age - 31.3 | Nutritional parameters | 24 mos, 55% recovered from iron deficiency
| Celiacs- 190 consecutive adults with iron deficiency anemia, 26 pts were diagnosed with CD after duodenal biopsy | Mean follow-up - 24 mos | Repeat endoscopy - 6 mos
| | 77% had total VA, 23% had subtotal atrophy
| | 11 did not have symptoms apart from anemia 42%
| | BMI
Arato, 2002 Hungary | Study type - longitudinal - own controls | Celiacs: n=17 | BMI | Before | After GFD | Short follow-up small sample size
| Population-group selection | % Females -59% | HbA1c | 16.8 <0.05 | | No controls
| Celiacs selected from 205 children with type 1 diabetes randomly selected, screened with EMA and then confirmed with biopsy | Mean follow-up - 3 mos | Insulin requirements | 7.82 NS
| Controls - no controls | BMI 14.2 vs 16.3 for controls | | 0.48 | 0.64 <0.05
| | 11 had silent CD, 6 had mild GI symptoms
Bardella, 1985 Italy | Study type - prospective | Celiacs - n=26 | Clinical Symptoms | 8 pts good health and normal blood tests and 18 had some clinical or biochemical abnormalities, 4 pts had recurrent abd pain, meteorism and diarrhea, 2 isolated episodes of diarrhea and 5 meteorism alone present, 11 pts had one more of anemia, moderate abnormal of calcium, alkaline phosphatase, phosphorus
| Population-group selection | Proportion F - 81% | CBC, biochemical parameters | 13 showed grade II, and 4 grade III - all improved by 1 or 2 grades but none returned to normal
| Celiacs- adults with biopsy confirmed disease (Grade II or IV - Scott/Losowsky) and malabsorption | Mean age - 42.2 | Repeat biopsy (17/26)
| Controls ---none | Mean follow-up- 55.4 mos on GFD (range 13–137 mos)
Bardella, 2000 Italy | Study type - case control | Cases 71 out of 212 | Weight | Lower than controls 55.5 vs 58.7 kg (p=0.004)
| 1962-1994 | 43 diagnosed as children, 28 as adults | BMI | 20.9 vs 22.4, p=0.03
| Population-group selection | Control - n=142 | Fat mass | 22.9 vs 27.5, p<0.05
| Celiacs not clear how selected | Proportion F - 72% | Lean mass | 38.8 vs 40.5 (p<0.03)
| 33.4% asymptomatic
| Controls - 2/pt matched for age and sex
Barera, 2000 Italy | Study type - case control prospective | Celiac cases - n=29 | Body composition - | At baseline, weight, fat mass, BMD, lean mass of limbs all lower in the pts versus controls, after 1 y no significant differences in body composition between pts and controls
| Population-group selection | Control - n=29 | DEXA | Untreated | Treated
| Celiacs - biopsy confirmed CD, 4 classic symptoms, remainder atypical | Age - 9.54 + 3.42 | Weight (kg) | 30.3 + 11.5kg | 34.7 + 12.3
| Controls - age and sex matched healthy controls | Proportion F: 51.7% | Height (cm) | 134.9 + 19 | 140.9 + 18.4
| | Mean follow-up - 1.20 ± 0.15 | BMI (kg/m2) | 16.7 +4.5 | 17.3 + 3.1
| | Compliance - EMA ab | Lean Mass | 166.8 | 179.9 +42
Boersma, Netherlands 2002 | Study type - 1994-1995 prospective study | Celiacs - 28 | BMI | BMI - SDS for CD improved significantly after a GFD over 1^st^ half year. (P<0.001) | With institution of GFD also noted increased sensitivity to GH, and levels of IGF-1, IGF-2, and IGFBP-3 rise
| Population-group selection Celiacs-children with newly diagnosed celiac (symptoms and biopsy confirmed) | Proportion F - 68% | BMI-SDS | Height for SDS for CD showed a continuous significant increment over the first 3 y of GFD (p<0.001)
| CD patients acted as own controls | Mean follow-up - 3 y | Height SDS
| | BMI
Ciacci, 1996 Italy | Study type - case control | Celiac - n=94 | Number of pregnancies/woman | 2.72 in untreated vs 1.36 in controls | RR of abortion 8.9 (95% CI 1.19, 31.9)
| Before after | Controls - n= 31 | Number of abortions/woman | 0.489 ± 0.08 untreated vs 0.032 ± 0.032 treated (17.8% vs 2.4%) | RR of low birth weight baby 5.84 (95% CI 1.07, 31.9) 12.7% vs2.4%
| Population-group selection | 12 separate women acted as own control for before after study to assess impact of the GFD (not included in other analysis). | Abortion to pregnancy ratio | 0.153 ± 0.027 vs 0.024 ± 0.024 | Did not have external control group or control for confounders.
| Celiacs | Mean age at diagnosis of untreated older than treated (37.3 vs 22.4) | Low birth weight baby to pregnancy ratio | 0.126 ± 0.037 vs 0.024 ± 0.024 (prevalence 12.7% vs 2.4% in treated)
| Untreated CD had a least one pregnancy when symptoms leading to diagnostic workup for CD were present | Mean follow-up of treated celiacs 9.2 ± 1.4 | | *controls not age matched - cases significantly older
| Controls (treated) had at least one pregnancy after 1 y of GFD | Mean weight of treated 50.6 vs 50
| Setting- Tertiary clinic | Mean BMI 20.1 vs 19.4
| | Clinical symptoms of untreated group33% did not have diarrhea, 24.5% did not have anemia
Fabiani, 1996 Italy | Study type - longitudinal | Celiacs - n=28 adolescents (age 11–14) | Compliance | 52% on strict GFD
| Population-group selection | Proportion F -74% | | 47% partial adherence
| Celiacs - biopsy proven CD from screening of adolescents (n = 6,315) | Mean F/U 23 ± 7 mos | | weight gain 12/23 (52%), height gain (11/25)
| Controls - none
| Loss to follow-up - 5
Fabiani, 2000 Italy | Study Type - case control | Celiacs | Compliance - FFQ conducted by dietician | Adherence to treatment lower in Group A (23%) asymptomatic versus Group B (68%) | *Difference in adherence could be related to age at diagnosis
| 1992-1994 | Group A n = 22 pts, asymptomatic | Anthropometric assessment | p value sig
| Population-group selection | Group B n = 22 pts symptomatic | | BMI no differences between groups
| Celiacs - selected from screening program for CD ages 11–14, Group A and second group B from pts diagnosed due to typical symptoms (biopsy proven ESPGAN) | Mean follow-up - 5 y
| Loss to follow-up: Group A 5 pts, Group B 2 pts | Age at diagnosis of CD: Group A 13y, Group B 4.3 y
Fickling, 2001, UK | Retrospective case-control study | CD pts: n=75; 15 with metabolic bone disease and CD | Fractures: | RR: 7.0 (95% CI 4.2–125) | Not population-based
| Group selection | Controls: n=75 | [underlined: CD pts]: 16/75 (21%), 10 before Dx, 6 after Dx | Increased history of past fractures in subjects with CD. (p<0.001) | Selection bias
| [underlined: CD pts]: All individuals with CD who attended gastroenterology output depart and those with CD who were member of local celiac society | Mean age of CD pts: 52 y | [underlined: Controls]: 2/74 (3%) | No difference in BMD in those with and without fractures, but pts who had a fracture were older (56.3 vs 50.3) | No mention that CD was confirmed by biopsy
| [underlined: Controls]: Age/sex matched controls/ one per case selected from database of normal adults who had a bone densitometry performed with the same machine | Proportion on GFD: full details n/r | BMD-DXA
| Institution: District general hospital | Median duration of GFD: 3.4 y | 6 pts had histomorphometry- 3 pts had osteomalacia
| Ascertainment of outcome: | Proportion of females: 80%
| By questionnaire on fracture history with attempt to verify by case notes | Clinical presentation: n/r
| Blinding: n/r | BMI: n/r
| Follow-up:
Greco, 1997 Italy | Study type- cohort | Celiac - 306 adolescent/young adults | Compliance - one month retrospective questionnaire | Three groups | 88.4% of younger teenagers on a strict diet vs 68.8% of older patients >18 y
| Population- | Cases of CD | | 1. Strict GFD 73% | Avg monthly cost GFD 242,000 Italian Lire, 3 million per year
| Celiac - biopsy confirmed pts (92.8%) consecutively recruited from a celiac clinic, 22 pts diagnosed on basis of immunological and clinical findings | Mean age - 15.9 (range 10–27) | | 2. Occasional relapse 15% | 11.32 kg/month
| | Proportion F - 60.8% | | 3. Full gluten containing 12%
| | Mean follow-up | | Females more compliant (80% vs 64% of males)
| | BMI
Johnston, 1998 N. Ireland | Study type-case control | Celiac n= 89 (72 followed) - 20 biopsied and 13 untreated detected | Mortality- overall and cancer | 13 subjects with positive serology died, 4 with malignant disease | Cancer death
| Longitudinal follow-up of cases | Controls 89 | Number of deaths compared to Registrar | No increase in all-cause mortality or number of cancer-related deaths in screening detected cases of CD | RR 0.94 (95% CI 0.3–2.4)
| 1983-1998 | Proportion F - 53 % | General's reports 1983-1994 | | All deaths
| Population-Group | Mean follow-up - 11.6 y | | | RR 0.92 (95% CI 0.5, 1.6)
| Selection- population survey | | | | Limitations
| Celiacs -screening detected CD of 1823 subjects with serology (n=113)- 3% also had inflammatory bowel disease | | | | Incomplete follow-up
| Controls - 89 age and sex matched randomly selected from survey - antibody negative | | | | Response rate for biopsy (20/72 is low)
| Ascertainment of outcome - death certificates
Kemppainen, 1998 Finland | Study type - cohort | Celiacs - 40 pts | Nutritional status examined by food records, and BMI | BMI increased after GFD, decreased intakes of fibre, thiamine | Baseline - serum ferritin lower in pts with total VA, also had low RBC folate, and ferritin
| Duration: 1988-1990 | Age - 47 for men and 44 for women | Ferritin/biochemical values | Most of abnormal biochemical values improved, in 1 pt with subtotal atrophy - low Hgb, in pts with subtotal VA - 7 pts had low Hgb and 5 low ferritin
| Population-group selection | Proportion F - 70% | Biopsy | After GFD - VA improved in all patients
| Celiacs: newly diagnosed biopsy confirmed, symptomatic, all started on GFD | Proportion on GFD -100% | | 29 pts had partial VA, 2 subtotal, 3 normal villi
| Partial (8), subtotal (17) and total VA (15) | Mean follow-up: 1 y
| Controls -none | Duration of CD symptoms - males 15.8, women 13.1
| Institution - Tertiary care Kuopio University Hospital | BMI 25 in men, and 24 in women
| Follow-up - 6 pts lost to follow-up
Moreno, 2004, Argentina | Case-control, cross sectional | CD pts: n=148 | Fractures: classic symptoms vs subclinical overall -51pts | OR 3.6 (95% CI 1.7–7.5) | Choice of controls-functional disorders/cases
| Group selection | unselected CD | Fractures-peripheral | OR for symptomatic pts | Fractures not verified by X-ray report
| [underlined: CD pts]: unselected 53% classic symptoms, 36% subclinical, 11% silent by screening | Controls: n=296 (2:1) | 47% symptomatic CD vs 15% controls | 5.2 (95% CI 2.8–9.8)
| [underlined: Controls]: 296 age and sex matched diagnosed with functional disorders | Mean age CD pts: | 20% subclinical/silent CD vs 14% controls | OR 1.7 (0.7–4.4)
| Institution: 2 different tertiary referral centres | Classic: 44 y | Mean BMD femoral neck | Fractures not any greater in subclinical cases of CD vs controls
| Ascertainment of fracture: in-person interview | Subclinical/silent: 38 y | | Higher for subclinical/silent cases vs classical p<0.05(T score -0.6 vs -1.5)
| | Age at diagnosis: | | Pts with CD-sig more fractures in 5th/6th decade; also sig more low trauma fractures than controls
| | Classic: 42 y
| | Subclinical/silent: 36 y
| | BMI:22/22.1
| | Proportion females: 79 %
| | Clinical presentation:
| | 53% classical CD; 35% subclinical, and 11% silent
Nielsen, 1985 Denmark | Study type - retrospective cohort | Celiac pts - 98 | Mortality | 5-y survival 88%, 10-y survival 68.5%(23 deaths, 4 deaths attributed to malignancy) 8 pts developed cancer | SMR 3.4
| Study dates 1964-82 | Proportion F - 61 % | | Responders to GFD - 2.2 extra mortality factor
| Population-group selection | Median age at diagnosis - 41 (F) and 42 (M) | | Non-responders to GFD - 5.8
| Celiacs - histologic diagnosis of CD - 100 | Mean follow-up - 18 y | | Compliance with diet - 3.2
| Ascertainment of outcome- Central person register, cancer registry | % refractory CD -24% treated with prednisone since did not respond to GFD | | Non compliant - 4.5
| Tertiary hospital | Compliance - not described how assessed
Poddar, 2002 India | Study type - case control longitudinal | Celiacs - n= 57 | Height | Height 88 ± 5% of expected vs 94 ± 5% of expected baseline and follow-up (p=ns) | Did not analyze on basis of compliance
| Period - 09/1997 - 12/1998 | Controls - n=47 | Weight gain | 66% ± 14 vs 86% ± 11 of expected (p<0.001) | Selection of cases
| Population-group selection | Proportion F - | Symptoms | Improved in 16 ± 9.8 days
| [underlined: Celiacs-]104 children with clinical symptoms evaluated for celiac disease, 57 biopsy confirmed. | Mean follow-up - 19.6 ± 8 mos | | 34% had poor compliance to diet
| Excluded those who did not have good response to diet | 17% poor compliance
| Controls -Those who did not have celiac on biopsy of the initial 104
Rea, 1996 Italy | Study type - case control longitudinal | Celiacs: n= 23 | Height, BMI | Height. BMI, triceps skinfold, fat area index, and weight for height index all improved significantly. | Compared to controls height still significantly lower
| Study dates 1992-1994 | Controls: n=23 | Weight, fat area index | Hgb, iron, protein, albumin, triglycerides, calcium and zinc significantly improvedTransferring, cholesterol, phosphorus and alk phos were not different
| Population-group selection | Proportion of F - 65.2% | Triceps subscapular skin fold
| Celiacs - newly diagnosed children, biopsy confirmed | Mean age 4.7 ± 0.76 | Biochemical values
| Controls-age and sex matched healthy controls | Mean follow-up - 1 y
| | Co-interventions
| | All patients received vitamin D 1000 IU
| | If iron was low, received iron supplementation
Sategna-Guidetti, 2001 Italy | Study type - longitudinal case control | Celiac - 241 | BMI | Similar in patients with and without thyroid disease | Improvements in BMI, nutritional indices, albumin and serum iron with GFD
| 1996-1998 | Proportion F - 73% | Thyroid function (serum fT3 and fT4 by RIA, TSH by IRA and thyroid microsomal antibodies | Thyroid dyfunction in 73/241 (30.3%) vs 11.3% (p<0.0005) Thyroid disease 3 × higher than controls | Gluten withdrawal (confirmed by biopsy recovery) seemed to normalize nonautoimmune thyroid disease
| Population-group selection | Controls - 212 | | Hypothyroidism diagnosed in 12.9% vs 4.2% of controls (p<0.003) | 5.5% of pts with normal thyroid function while untreated developed thyroid dysfunction one y later
| Celiacs consecutive newly diagnosed CD patients, biopsy proven | Mean follow-up- 1 y | | 128 pts reassessed at 1 y91 had normal thyroid, 37 some impairment
| Controls - age, sex matched healthy volunteers recruited among medical and nursing staff, blood donors or pts affected by COPD, peptic ulcer disease, no past history of thyroid dysfunctionExcluded conditions that could affect thyroid function, excluded CD by means of EMA or biopsy | Clinical presentation | | Subclinical hypothyroidism improved in 71% patients with nonautoimmune thyroid disease
| Setting- 5 Italian centres | Typical in 49%, atypical in 44% and silent in 16%
Saukkonen, 2002 Finland | Study type - longitudinal | Celiacs/type 1 diabetes n = 18 | HbA1c | No change in HbA1c levels with GFD | Significant increase in weight for height after diagnosis
| Population-group selectionCeliacs, screened 776 children with type 1 diabetes with serology/biopsy (over 2.7 y period) - own controls | Mean onset of diabetes - 8.0 ± 4.5 y | GI symptoms | Symptoms which were reported in a retrospective questionnaire resolved in all but 2 pts | No changes in Ht SDS
| Controls - none | Proportion F - 50%
| | Mean follow-up - 1 y
Smecuol, 1997 Argentina | Study type - longitudinal | Celiac - 47 and 25 pts re-evaluated in 1995 | Fat and bone mass | Significant increase in fat/bone mass
| Dates - 1991-1993 | Proportion F - | Lean tissue mass | No change in lean tissue mass
| Population-group selection | Mean follow-up - 37 mos | Weight and tricep skin fold thickness | Increases in body weight/triceps skinfold thickness
| Celiacs unselected consecutive patients with newly diagnosed CD, all were symptomatic, and biopsy confirmed acted as own controls | Compliance- 15 pts - strict | Mid arm circumference and muscle mass
| | GFD, 10 partial GFD
| | BMI
Thomason, 2003, UK | Case-control study | CD pts: n = 244 (70% females) | Fractures - low trauma (fall from a standing height or less) | OR 1.05 (0.68–1.02) | Retrospective
| Self-report data from questionnaire. | Controls n=161 | Any fracture: | OR1.21 (0.66–2.25) | Self- report data
| Group selection: | Mean age: | CD: 82 (34.5%) | OR 1.16 (0.65–2.10) | Response rate to questionnaire was 72% in controls, 89% in celiacs
| [underlined: CD pts:] all biopsy-proven CD (also clinical/serology) from population based registers for Derby and Nottingham (less than 7% did not have a bx) Only pts born prior to 1950 included. | CD: 60.2 y (10.1) | Control: 53 (33.3%) | When adjusted age, sex, BMD and smoking the OR 1.13 (95% CI 0.6–2.12) | Inadequate power to detect fractures
| [underlined: Controls]: age/sex matched random sample from Nottingham family health services. | Controls: 61.2 y | Forearm/wrist: | Before Dx: HR 1.24 (95% CI 0.65 – 2.39)
| Ascertainment of fractures: | Mean BMI: | CD: 39 (16.4) | Small but statistically-significant increase in risk of fractures
| Self-report of low trauma and non low trauma fractures | CD: 23.9 | Control: 22 (13.8)
| Blinding: | Controls: 25.8 | Low trauma fracture:
| Investigator who categorized fractures as low trauma or not was blinded to whether case or control | Proportion of females: 70% | CD: 37 (15.7%)
| | Proportion on GFD: n/r | Control: 21 (13.8%)
| | Clinical presentation: n/r | (20 reported first fracture before diagnosis of CD and 10 pts reported first fracture after diagnosis)
| | Dx of osteoporosis: 7.4% of cases versus 3.1% of controls | Logistic regression to estimate odds ratio for fracture - adjusted for sex and age group
| | Smokers: | Cox's proportional Hazard model was used and only first low trauma fracture was included.
| | CD: 52.5%
| | Controls: 43.3%
| | Cointerventions:
| | 4% of CD pts reported taking calcium
| | HRT: 31% vs 21% of controls (significant), adjusted for HRT use in analysis
Vasquez, 2000, Argentina | Cross-sectional case-control study | CD pts: n=165 | Fractures | OR: Peripheral fractures (25%) of CD pts and (8%) of controls; 3.5 (95% CI 1.8–7.2) p<0.0001, wrist most common | Cases were from a malabsorption clinic and therefore may have included subjects with more severe disease
| Retrospective historical review | Median Age: | Peripheral: | Vertebral fractures
| Group selection | CD: 40 (16–74) y; 23% over 50 y | [underlined: Cases:] 41 (25%) | 4/78 (5%) of controls versus 9/68 (13%); OR 2.8 (0.7, 1.15) incomplete ascertainment
| [underlined: CD pts]: All biopsy-proven celiac disease, and clinical picture, excluded those with secondary osteoporosis other than celiac | Mean age of controls: 41 y | [underlined: Controls:] 14 (8%) | X-rays: 68 pts and 78 controls were adequate quality
| [underlined: Controls]: 165 subjects selected from output clinic and selected if their final diagnosis was a functional disorder. Excluded cases with known metabolic bone disorders | Median time from symptoms to diagnosis: 7 y | Total number of fractures: 51 in celiacs/15 in controls | Most fractures observed pre-diagnosis
| Institution: Single institution | Proportion of females: 86.6% | BMD: | Only 7% of pt developed fractures after starting GFD
| Buenos Aires -tertiary hospital | Proportion on GFD: 69% | Lower in those with fractures (non-significant)
| Ascertainment of fracture | Strict GFD: 44.8% | Exclusions:
| Pt interview, case report | Reduced gluten: 24% | Only lumbar spine X-rays from 68 pts and 78 controls were considered to be of adequate quality
| Vertebral fractures -X-ray of lumbar spine (not thoracic) in all CD and 62% of controls | Untreated: 31%
| Did not have medical records of trauma events | Mean BMI: 21.4
| Blinding: n/r | Clinical presentation:
| | malabsorption or subclinical
| | Post-treatment biopsy:
| | histological improvement in 38 pts
| | Serology:
| | negative or reduced titres in all with positive serology
Vestergard, 2002, Denmark | Retrospective cohort study, population based | CD pts: n=1,021; 7,774 PY | All Fractures: CD vs control | Incidence rate ratio (ALL) | Used only hospital-based discharge data therefore could miss output fractures (wrist, rib)
| Study dates: 1983-1996 | Controls: n=23; 316 PY | Before diagnosis: 24/7774 PY vs 103/23,316 PY | Before Dx: 0.70 (0.45,1.09) | Based on assumption that majority of pts pre 1996 hospitalized early in course of disease
| Group selection | Mean age at diagnosis: 31.5 y (24.7) | After diagnosis: 65/6,675 vs 223/21,468 PY | After Dx : 0.94 (0.71, 1.24) | Validity of diagnosis verified in random sample and was low (78%) n=9 therefore potential for misclassification
| [underlined: CD pts]: All individuals admitted/ discharged with a CD Dx (ICD -8) | Mean follow-up: 7,774 PYs cases; 23,316 controls | Spine Rib Pelvis | (spine, rib, pelvis) | Selection of controls Some of controls had diseases that may have increased fracture risk
| [underlined: Controls]: 3 controls per case population age and sex matched | Proportion of females: 58% | Osteoporosis | IRR 2.14 (0.70, 6.57) pre
| Institution: Danish hospitals | Proportion on GFD: n/r | | IRR 1.07 (0.39, 2.95) post
| Ascertainment of fracture | Compliance: n/r | | IRR 3.00 (0.21,41.9) pre
| National pt discharge register-any fracture registered during hospitalization | Clinical presentation: symptomatic (admission to hospital) | | IRR 1.29 (0.4, 4.09) post
| Confounders: not examined | BMI: n/r
| Blinding: n/r | Age at first fracture after diagnosis: 40.2 y
| Comorbidity examined by assessing hospital admissions for conditions that may alter risk of fractures. (2.8% in CD vs 2.6% in controls) | Exclusions
| | ? output diagnosis of CD
West, 2003, UK | Retrospective matched cohort study | CD pts: n=4,732 observ. time (27,116) | Fracture: CD vs control | HR: 1.30 (95% CI, 1.16,1.46) (report prevalent and incident) | Celiacs more frequent attenders, ?overestimate rate of some fractures relative to controls
| Study dates: 1987-2002 | Controls: n=23,620 (149,896 y of risk) | Any fracture: | HR 1.9 (1.20,3.02) | Misclassification - accuracy of diagnosis of CD
| Group selection | Mean age at diagnosis | 356/4732 vs 1524/23616 | HR 1.77 (1.35,2.34) | ? Less likely in UK, since GPs not likely to write prescription for GFD
| [underlined: Pts with CD]: All recorded Dx of CD recorded 1-yr after beginning of the GPRD record; no biopsy data | celiac: 43.5 y | 137.9/10,000 PYs vs 105.9/10,000 in controls | Absolute diff in overall fracture rate was 3.2/1000 person y
| [underlined: Controls]: matched by age, sex, general practice and follow-up time, excluded any who had record of a gluten-free prescription | Range of age: n/r | Hip: 8.9/10,000 PY versus 4.7/10,000 PY | 0.97/1000 for hip fracture in those >45 y
| Primary care database: GPRD established in 1987 | Proportion of females: 67% | Ulna/radius fracture:
| Ascertainment of fracture: Admin database | Proportion smoke: 13% (controls 15.4%) | 24.9/10,000 versus 14.1/10,000
| Blinding: n/r | Mean follow-up: 5.7 y, # | No difference in risk of fracture in period after diagnosis compared to before diagnosis
| Examined potential confounders | PYs: 27,116
| | 10% of cohort did not receive a prescription for GFD, 36% 0–10 and 54≥10
| | BMI:
| | [underlined: Celiacs]: <25 – 47%
| | [underlined: Controls]: <25: 30.6% ≤18.5; 4.2% vs 1.2% of controls
Westman 1999 Australia | Study type- | Cases 20 | Height SDS | No difference in height
| Population-coexisting type 1 diabetics and CD identified from database of Diabetes Center-biopsy proven | Control 40 | Weight SDS | SDS, weight SDS or BMI SDS
| Controls- 40 matched for age and sex and duration of IDDM | Duration of diabetes: 7.2 vs 7.3 y controls | BMI SDS | 8.48 ± 0.98% for CD vs 8.87 ± 1.46 for controls
| | % F - 75% | HbA1c | 30% strict GF, 30% trace gluten and 40% significant amt of gluten
| | Mean follow-up | Compliance
| | Compliance with FFQ

## Celiac 5: Promoting or Monitoring Adherence to a GFD

Evidence Table 12: Promoting or monitoring adherence to a GFD

Author, Year, Location | Study Design | Study Population | Outcomes | | | | Comments
| | | Time 1 | Time 2 | Time 3 | Time 4
Anson, 1990, Israel | Publication type: | Celiac Group 1 | Baseline | | | | Compliance correlated with father being professional/parental education/parental ability to choose GF items from menu.
| journal | • 31 children judged GFD compliant based on symptoms and/or serology and/or biopsy | Biopsy
| Study design: | • age: n/r | AGA
| Parental questionnaire | • %F: n/r | EMA
| Ethnicity: | Celiac Group 2 | tTG
| n/r | • 12 children judged non-compliant with GFD
| Population type: | • age: n/r
| Jewish children with CD | • %F: n/r
| Biopsy criteria:
| n/r
| Checked IgA def.
| no
| Serologic tests:
| [underlined: Test name:]
| n/a
| [underlined: Methodology:]
| n/a
| [underlined: Cut-off:]
| n/a
Bardella, 2001, Italy | Publication type: | Celiac Group 1 | Baseline | | | | Serology falls with increasing length of compliance with GFD. No biopsy to correlate serology with in this study.
| journal | • 40 pts, untreated CD | Biopsy
| Study design: | • mean age: 38 y (range 16–77 y) | AGA
| case-control | Celiac Group 2 | Group 1 95%; Group 2 100%; Group 3 40.9%; Group 4 16.2%; Control 10.9%
| Ethnicity: | • 25 CD; poor GFD compliance | EMA
| n/r | • age: n/r | 100%; 100%; 54.5%; 9.5%; 2.7%
| Population type: | • gender: n/r | [underlined: t]TG
| CD: details of diagnosis n/r | Celiac Group 3 | 100%; 100% 63.6%; 14.2% 1.8%
| Biopsy criteria: | • 22 CD. Compliant GFD<2 y
| Marsh | • age: n/r
| Checked IgA def. | • gender: n/r
| Yes, excluded | Celiac Group 4
| Serologic tests: | • 148 CD. Compliant GFD >2 y
| [underlined: Test name:] | • age: n/r
| IgA-AGA; IgA-EMA; IgA-tTG | gender: n/r
| [underlined: Methodology:] | Control
| n/r; ME; GP liver | • 110 non-CD controls
| [underlined: Cut-off:] | • age: nr
| 12 AU/mL; 1:10; 10 AU/mL | • gender: n/r
Bartholomeus, 1990, Australia | Publication type: | Celiac Group 1 | Baseline | | | | PPV of IgA AGA for non-compliance 78.5% for pts on GFD > 6 mos. How compliance ascertained not described.
| journal | • 17 CD. GFD >6 mos adults and children | Biopsy
| Study design: | • age: n/r | AGA
| cohort | • gender: n/r | Group 1 3 (17%); Group 2 11 (92%)
| Ethnicity: | Celiac Group 2 | EMA
| n/r | • 12 adults and children with CD on gluten | tTG
| Population type: | • age: n/r
| CD: details of diagnosis n/r | • gender: n/r
| Biopsy criteria:
| Adults partial VA, subtotal VA, total VA; children ESPGAN
| Checked IgA def.
| No
| Serologic tests:
| [underlined: Test name:]
| IgA-AGA
| [underlined: Methodology:]
| n/r
| [underlined: Cut-off:]
| n/r
Burgin-Wolff, 1991, Switzerland | Publication type: | Celiac Group 1 | Baseline | GC 36 to 90 d | GC 3 to 12 mos | GC > 3 y | With gluten challenge IgA AGA and EMA seroconversion. AGA rises faster but positivity wanes with time.
| journal | • 134 children CD on GFD | Biopsy
| Study design: | • mean age: n/r (range 3–18 y) | AGA
| case-control | • gender: n/r | 23% IgA-AGA | 97% | 5% | 49%
| Ethnicity: | | EMA
| n/r | | 13% EMA | 65% | 84% | 93%
| Population type: | | tTG
| Classic CD
| Biopsy criteria:
| CD if subtotal VA, total VA
| Checked IgA def.
| no
| Serologic tests:
| [underlined: Test name:]
| IgA-AGA; IgA-EMA
| [underlined: Methodology:]
| n/r; ME
| [underlined: Cut-off:]
| n/r; 1:10
Dickey, 2000, Northern Ireland | Publication type: | Celiac Group 1 | Baseline | GFD 3 mos | GFD 6 mos | GFD 12 mos | EMA failed to detect VA in a significant number. These cases were felt to have VA due to non-compliance.
| journal | • 53 pts | Biopsy | | | 20 normal;1 Marsh 1 (high IEL); 22 partial VA; 10 total VA or subtotal VA
| Study design: | • mean age: 55; range 16–80 y | 12 partial VA; 21 subtotal VA; 21 total VA
| prospective cohort | • 74% F | AGA
| Ethnicity: | | EMA
| n/r | | 100% | 42% | 25% | 0% normal; 0% Marsh 1; 2 (9%) partial VA; 3 (30%) subtotal/total VA
| Population type: | | tTG
| Adults with classic CD
| Biopsy criteria:
| Marsh
| Checked IgA def.
| Yes. Excluded
| Serologic tests:
| [underlined: Test name:]
| IgA EMA
| [underlined: Methodology:]
| ME
| [underlined: Cut-off:]
| >1:5
Fabiani, 1996, Italy | Publication type: | Celiac Group 1 | Baseline | | | | Among pts reporting dietary transgressions 9 of 11 (81%) had normal AGA and EMA.
| journal | • 12 children reporting strict GFD | Biopsy
| Study design: | • age: n/r | AGA
| retrospective cohort | • gender: n/r | EMA
| Ethnicity: | Celiac Group 2 | tTG
| n/r | • 11 children reporting non-compliance
| Population type: | • age: n/r
| CD identified by screen | • gender: n/r
| Biopsy criteria:
| no description
| Checked IgA def.
| No
| Serologic tests:
| [underlined: Test name:]
| IgA AGA; IgA EMA
| [underlined: Methodology:]
| n/r
| [underlined: Cut-off:]
| n/r
Fabiani, 2000, Italy | Publication type: | Celiac Group 1 | Baseline | | | | 5 (23%) identified by screen reporting strict GFD. 15 (68%) of controls reporting strict GFD? Less compliant if screened CD.
| journal | • 22 children CD identified by screen | Biopsy
| Study design: | • mean age: 17.9 y; range: n/r | AGA
| case-control | • 59% F | EMA
| Ethnicity: | Control | tTG
| n/r | • 22 children with classic CD on GFD
| Population type: | • mean age: 16 y; range: n/r
| CD identified in a mass screen | • 59% F
| Biopsy criteria:
| ESPGAN
| Checked IgA def.
| No
| Serologic tests:
| [underlined: Test name:]
| n/a
| [underlined: Methodology:]
| n/a
| [underlined: Cut-off:]
| n/a
Fabiani, 2001, Italy | Publication type: | Celiac Group 1 | Baseline | | | | tTG value higher in higher Marsh lesions. Values tend to be higher in pts admitting dietary transgressions.
| journal | • 176 pt new diagnosis CD | Biopsy
| Study design: | • mean age: 16.4 y; range 0.3–87.4 y | Group 1: 0 Marsh 1, 29 (16%) Marsh 2, 145 (84%) Marsh 3
| case-control | • 65% F | Group 2: n/a
| Ethnicity: | Celiac Group 2 | Control: n/a
| n/r | • 172 CD on GFD > 1 | AGA
| Population type: | • mean age: 17.6 y; range 0.3 – 89.8 y | EMA
| Classic CD | • 66% F | tTG
| Biopsy criteria: | Control | Group 1: mean tTG Marsh 2 16 AU, Marsh 3 22 AU
| Marsh | • 206 healthy and non-CD | Group 2: strict GFD 4.2 AU, GFD transgressions 9.9 AU
| Checked IgA def. | • mean age: 15.6 y; range 0.4–78 y | Control: 2.7 AU
| Yes. Excluded | • 50% F
| Serologic tests:
| [underlined: Test name:]
| IgA-tTG
| [underlined: Methodology:]
| GP liver
| [underlined: Cut-off:]
| 7 AU
Fotoulaki, 1999, Greece | Publication type: | Celiac Group 1 | Baseline | GFD 12 mos | GC 6 mos | | Study suggests that after 1 y GFD, AGA and EMA predict Marsh 0 or 1 lesion. Significance of Marsh 1 unclear.
| journal | • 30 CD | Biopsy
| Study design: | • mean age: n/r; range 1–24 y | n/r | 100% Marsh 0 or 1 (breakdown not given ) | All Marsh 2 or 3 (breakdown not given )
| prospective cohort | • 57% F | AGA
| Ethnicity: | Celiac Group 2 | IgG AGA 100%; 90% IgA AGA | 40% IgG AGA; 0% IgA AGA | 100% IgG: 90% IgA
| n/r | • median age: (range: ) | EMA
| Population type: | • % F: | 100% | 0% | 90%
| Classic and atypical CD | | tTG
| Biopsy criteria:
| ESPGAN
| Checked IgA def.
| yes
| Serologic tests:
| [underlined: Test name:]
| IgG AGA; IgG AGA; IgA EMA
| [underlined: Methodology:]
| n/r; ME
| [underlined: Cut-off:]
| 0.3 control; 0.3 control; 1:2.5
Hogberg, 2003, Sweden | Publication type: | Celiac Group 1 | Baseline | | | | 12/15 (80%) diagnosed before age 4 judged GFD compliant (serology/questionnaire) vs. only 5/14 (36%) diagnosed after age 4.
| journal | • 29 adults diagnosed as a child | Biopsy
| Study design: | • mean age: 26 y; range 19–34 y | AGA
| retrospective cohort | • 69% F | EMA
| Ethnicity: | | tTG
| n/r
| Population type:
| Classic CD
| Biopsy criteria:
| ESPGAN
| Checked IgA def.
| no
| Serologic tests:
| [underlined: Test name:]
| IgG-EMA; IgA-EMA; tTG
| [underlined: Methodology:]
| ME; GP
| [underlined: Cut-off:]
| 1:10;1:10;>25 AU
Jacksoan, 1985, Ireland | Publication type: | Celiac Group 1 | Baseline | | | | GFD judged by parental questionnaire correlated with parental membership in Celiac society, parental knowledge of CD.
| journal | • 50 children CD | Biopsy
| Study design: | • median age: 9.9 y; range 1.5–19 y | AGA
| questionnaire | • 58% F | EMA
| Ethnicity: | | tTG
| n/r
| Population type:
| Classic CD
| Biopsy criteria:
| CD if severe VA and gluten response
| Checked IgA def.
| no
| Serologic tests:
| [underlined: Test name:]
| n/a
| [underlined: Methodology:]
| n/a
| [underlined: Cut-off:]
| n/a
Kaukinen,2002, Finland | Publication type: | Celiac Group 1 | Baseline GFD median 1 y | | | | tTG sens 41%
| journal | • 87 pts on GFD | Biopsy | | | | spec 88% PPV
| Study design: | • mean age: 49 y; range 22–73 y | 60 (69%) Marsh 0-II; 27 (31%) Marsh III | | | | 61% NPV 77%
| prospective cohort | • 72% F | AGA | | | | EMA sens 26%
| Ethnicity: | | EMA | | | | spec 93% PPV
| n/r | | 7 (26%) in Marsh III | | | | 63% NPV 74%
| Population type: | | tTG
| Classic CD | | 11 (41%) in Marsh III
| Biopsy criteria:
| Marsh
| Checked IgA def.
| Yes. Excluded
| Serologic tests:
| [underlined: Test name:]
| IgA-EMA; IgA-tTG
| [underlined: Methodology:]
| HU; GP liver
| [underlined: Cut-off:]
| 1:5; 1:20
Lamontagne, 2001, Canada | Publication type: | Celiac Group 1 | Baseline | | | | Older age (p<.05) & high level of confidence in treatment information from gastroenterologists & dieticians (p<.005) assoc. compliance.
| journal | • 234 CD. Members of Quebec Celiac Foundation | Biopsy
| Study design: | • mean age: 49 y; range 18–84 y | AGA
| questionnaire | • 75% F | EMA
| Ethnicity: | | tTG
| n/r
| Population type:
| Biopsy criteria:
| Checked IgA def.
| Serologic tests:
| [underlined: Test name:]
| n/a
| [underlined: Methodology:]
| n/a
| [underlined: Cut-off:]
| n/a
Lee, 2003, USA | Publication type: | Celiac Group 1 | Baseline | 1–14 y after initial Dx: only 12 pts re-biopsied; 31/39 had serology | | | Persistent abnormal biopsy on GFD. Only 21% had normal duodenal biopsy; serology was negative despite some VA in most.
| journal | • n=39 pts on GFD | Biopsy | IEL/100 epithelial cells-38; villous height to crypt ratio improved in all but one; none normalized
| Study design: | • mean age: 52 y; range 20–74 y | Normal 8 (21%); partial VA 27 (69%); total VA 4 (10%); IEL/epithelial cells 61 | 7; IgG only 4; IgG and IgA in 3
| retrospective cohort | • 60% F | AGA | 1 of 31
| Ethnicity: | | EMA
| n/r | | tTG
| Population type:
| Classic CD
| Biopsy criteria:
| Normal, partial VA or total VA
| Checked IgA def.
| n/r
| Serologic tests:
| [underlined: Test name:]
| IgG AGA; IgA AGA; IgA AMA
| [underlined: Methodology:]
| n/r
| [underlined: Cut-off:]
| n/r
Ljungman, 1993, Sweden | Publication type: | Celiac Group 1 | Baseline | | | | Self-assessed GFD compliance correlated with knowledge as scored on a test and with a feeling of being well informed.
| journal | • 47 children born between 1973-78 | Biopsy
| Study design: | • mean age: n/r | AGA
| questionnaire | • gender: n/r | EMA
| Ethnicity: | | tTG
| n/r
| Population type:
| Classic CD
| Biopsy criteria:
| ESPGAN
| Checked IgA def.
| n/r
| Serologic tests:
| [underlined: Test name:]
| n/a
| [underlined: Methodology:]
| n/a
| [underlined: Cut-off:]
| n/a
Martini, 2002 Italy | Publication type: | Celiac Group 1 | Baseline (at diagnosis) | GFD 1 y +/- 1mos | | | Poor concordance between biopsy and serology after GFD for one year. GFD led to a significant decrease in majority.
| journal | • 109 CD on GFD 1 y | Biopsy
| Study design: | • median age: 37 y; range 21–72 y | 6 (6%) Marsh 2; 95 (95%) Marsh3 | 12 (12%) normal; 51 (50%) Marsh 1; 38 (38%) Marsh 2 or 3
| prospective cohort | • 78% F | AGA
| Ethnicity: | | n/a | n/a
| n/r | | EMA
| Population Type: | | n/a | Concordance (both biopsy/EMA + or both) 48%
| Classic CD | | tTG
| Biopsy criteria: | | n/a | Concordance 29%; 65%;14%; 16%; 19%
| Marsh
| Checked IgA def.
| n/r
| Serologic tests:
| [underlined: Test name:]
| IgA-EMA; IgA-tTG-1; tTG-2, tTG-3, tTG4, tTG-GP
| [underlined: Methodology:]
| ME; HU; HU; HU; HU; GP
| [underlined: Cut-off:]
| 1:5; n/r
McNichol, 1976, Ireland | Publication type: | Celiac Group 1 | Baseline | | | | IEL count higher in CD with slight damage than no damage (p<.005) or controls (p<.001)
| journal | • 36 children on GFD (mean 6 y) | Biopsy
| Study design: | • mean age: n/r; range 2.75–11 y | Group 1–16 (44%) normal. 20 (56%) slight mucosal damage; controls all normal
| cohort | • gender: n/r | AGA
| Ethnicity: | Control | EMA
| n/r | • 25 normal siblings | tTG
| Population type: | • mean age: 9.9; range: 4–18
| Classic CD | • gender: n/r
| Biopsy criteria:
| Normal, slight, moderate, severe mucosal damage
| Checked IgA def.
| n/r
| Serologic tests:
| [underlined: Test name:]
| n/a
| [underlined: Methodology:]
| n/a
| [underlined: Cut-off:]
| n/a
Pacht 1995, Israel | Publication type: | Celiac Group 1 | Baseline 22 GCD;17 GFD | | | | EMA titre monitored longitudinally in 10 pts correlated with gluten intake. EMA correlated with investigator gluten assessment.
| journal | • 39 CD, 22 GCD and 17 GFD | Biopsy
| Study design: | • mean age: 10 y; range: n/r | n/r; histology available on 5 on GFD - all normal
| retrospective cohort | • % F: 46% | AGA
| Ethnicity: | Celiac Group 2 | EMA
| n/r | • median age: (range: ) | 22/22 GCD EMA+; 0/17 GFD EMA+
| Population Type: | • % F: | tTG
| Classic CD
| Biopsy criteria:
| ESPGAN
| Checked IgA def.
| n/r
| Serologic tests:
| [underlined: Test name:]
| IgA EMA
| [underlined: Methodology:]
| ME
| [underlined: Cut-off:]
| >1:2.5
Sategna-Guidetti, 1996, Italy | Publication type: | Celiac Group 1 | Baseline | GFD 8–30 mos | | | EMA PPV for abnormal histology 100%, NPV 23%; AGA (total) PPV for abnormal histology 93.8%, NPV 25%
| journal | • 47 pts | Biopsy
| Study design: | • mean age: n/r; range: 18–68 y | 0 normal; 1 (2.1%) partial VA; 11 (23%) subtotal VA; 35 (74%) total VA | 9 (19%) normal; 23 (49%) partial VA; 13 (28%) subtotal VA;2 (4%) total VA
| prospective cohort | • 55% F | AGA
| Ethnicity: | | 39 (83%) | AGA measured in 39; Bx normal: 1/7 AGA+; partial VA: 7/20; subtotal VA: 5/10; total VA: 2/2
| n/r | | EMA
| Population Type: | | 47 (100%) | Bx normal: 0 EMA+; partial VA: 5/23; subtotal VA: 3/13; total VA: 1/2
| CD: details of diagnosis not reported | | tTG
| Biopsy criteria: | | n/a
| Normal, partial VA, subtotal VA, total VA
| Checked IgA def.
| Yes, excluded
| Serologic tests:
| [underlined: Test name:]
| total AGA; IgA EMA
| [underlined: Methodology:]
| n/r; ME
| [underlined: Cut-off:]
| n/r
Scalici, 2003, Italy | Publication type: | Celiac Group 1 | Baseline (at diagnosis) | GFD for 6 mos | | | Only 11.1% EMA + if 1 dietary transgression/ mos (after 6 mos GFD). 19% EMA + if 1 or more dietary transgressions per week
| journal | • 61 CD pts | Biopsy
| Study design: | • mean age: n/r; age range 2–27 y | n/r | n/a
| prospective cohort | • %F: n/r | AGA
| Ethnicity: | Celiac Group 2 | EMA
| n/r | • median age: (range: ) | 0 EMA+ | 2/16 (12.5%) reporting strict GFD EMA+; 5/45 (11.1%) admitting dietary mistakes EMA+
| Population type: | • % F: | tTG
| Classic CD
| Biopsy criteria:
| ESPGAN
| Checked IgA def.
| n/r
| Serologic tests:
| [underlined: Test name:]
| IgA EMA
| [underlined: Methodology:]
| n/r
| [underlined: Cut-off:]
| n/r
Selby, 1999 Australia | Publication type: | Celiac Group 1 | Baseline | | | | VA persisted at high rates after prolonged GFD (whether Codex diet allowing .03% protein from gluten or on no detectable GFD)
| journal | • 89 pts CD on GFD mean 8.3 y | 39 Codex diet; 50 no detectable gluten
| Study design: | • mean age: 47 y; range: 20–75 | Biopsy
| cross sectional | • 82% F | 18/39 (46%) VA; 20/50 (40%) VA
| Ethnicity: | | AGA
| n/r | | EMA
| Population Type: | | tTG
| Classic CD
| Biopsy criteria:
| Normal, partial VA, subtotal VA, total VA
| Checked IgA def.
| n/r
| Serologic tests:
| [underlined: Test name:]
| n/a
| [underlined: Methodology:]
| n/a
| [underlined: Cut-off:]
| n/a
Troncone, 1995 Italy | Publication type: | Celiac Group 1 | Baseline | | | | EMA often did not pick up mild dietary transgressions despite mucosal abnormalities including VA.
| journal | • 4 CD on strict GFD (23 in overall study | Biopsy
| Study design: | • mean age: 14.5 y; range 10–19 y | Group 1 4/4 normal; Group 2 3/6 high IEL, 1/6 VA; Group 3 5/6 high IEL 3/6 VA; Group 4 7/7 VA
| cohort | • 35% F) | AGA
| Ethnicity: | Celiac Group 2 | EMA
| n/r | • 6 pts <0.5 g/d gluten | Group1 0/4; Group 2 1/6; Group 3 3/6; Group 4 7/7
| Population Type: | • median age: n/r; range: n/r | tTG
| CD : details of diagnosis not reported | • % F: n/r
| Biopsy criteria: | Celiac Group 3
| Normal, partial VA, subtotal VA, total VA | • 6 pts 0.5–1.0 g/d gluten
| Checked IgA def. | • median age: n/r; range: n/r
| n/r | • % F: n/r
| Serologic tests: | Celiac Group 4
| [underlined: Test name:] | • 7 pts>2 g/d gluten
| IgA EMA | • median age: n/r; range: n/r
| [underlined: Methodology:] | • % F: n/r
| ME
| [underlined: Cut-off:]
| >1:5
Vahedi, 2000 France | Publication type: | Celiac Group 1 | Baseline (39% strict GFD) | | | | EMA and tTG often negative despite dietary transgression. EMA 37% sensitive for minor transgression. tTG 31% sensitive.
| abstract | • 137 CD on GFD>1 y - median 75 mos | Biopsy
| Study design: | • median age: 46 y; range 18–74 y | n/a
| cross sectional | • 76% F | AGA
| Ethnicity: | | EMA
| n/r | | 2.5% strict GFD; 37% minor transgression; 86% major transgression
| Population type: | | tTG
| CD: details of diagnosis not reported | | 3% strict GFD; 31% minor transgression; 77% major transgression
| Biopsy criteria:
| no description
| Checked IgA def.
| Yes. Excluded
| Serologic tests:
| [underlined: Test name:]
| IgA EMA; IgA tTG
| [underlined: Methodology:]
| n/r
| [underlined: Cut-off:]
| 1:5; n/r
Valentini, 1994, Italy | Publication type: | Celiac Group 1 | Baseline GFD > 6 mos | | | | 17/24 EMA negative after 6 mos on a GFD despite VA on biopsy
| journal | • 33 CD pts on GFD >6 mos- mean 9 mos | Biopsy
| Study design: | • mean age: n/r; range: n/r | 8 normal; 21 partial VA; 4 subtotal VA
| prospective cohort | • % F: n/r | AGA
| Ethnicity: | | EMA
| n/r | | 9 (27%). Of 73% EMA negative, 7 normal,14 partial VA,3 subtotal VA
| Population Type: | | tTG
| Classic and atypical CD
| Biopsy criteria:
| Normal, partial VA, subtotal VA
| Checked IgA def.
| n/r
| Serologic tests:
| [underlined: Test name:]
| IgA EMA
| [underlined: Methodology:]
| ME
| [underlined: Cut-off:]
| >1:5
Valetta, 1990 Italy | Publication type: | Celiac Group 1 | Baseline | | | | With GC, most AGA+ which prompted Bx showing VA in all. Does not necessarily mean compliance could be monitored.
| journal | • 17 pts given gluten challenge | Biopsy
| Study design: | • mean age: n/r; range 3 – 11 y | at 20–45 d, all had moderate or severe VA
| prospective cohort | • 59% F | AGA
| Ethnicity: | | 16/17 (94%) after 15 – 35 d gluten challenge
| n/r | | EMA
| Population type: | | tTG
| CD: details of diagnosis not reported
| Biopsy criteria:
| N, slight VA, moderate VA, severe VA
| Checked IgA def.
| n/r
| Serologic tests:
| [underlined: Test name:]
| IgA AGA
| [underlined: Methodology:]
| n/r
| [underlined: Cut-off:]
| >3 SD controls
Wahab, 2002, unknown | Publication type: | Celiac Group 1 | Baseline | GFD <2 years | GFD 2–5 years | GFD >5 years | Overall, only 65% recovery within 2 y. 10% with no recovery after 5 y. Recovery defined as no VA ( Marsh 0–2).
| journal | • 158 pts | Biopsy | 88% 3a recovery to 0–2; 58% 3b recovery; 81% 3c recovery | 98% 3a recovery to 0–2; 78% 3b recovery; 81% 3c recovery | 98% 3a recovery to 0–2; 88% 3b recovery; 86% 3c recovery
| Study design: | • mean age: 44 y; range 0 – 74 y | 59 (37%) Marsh 3a; 59 (37%) 3b; 40 (25%) 3c
| retrospectve cohort | • 91% F | AGA
| Ethnicity: | Celiac Group 2 | EMA
| n/r | • median age: (range: n/r ) | tTG
| Population type: | • % F:
| Classic CD
| Biopsy criteria:
| Marsh
| Checked IgA def.
| No
| Serologic tests:
| [underlined: Test name:]
| n/a
| [underlined: Methodology:]
| n/a
| [underlined: Cut-off:]
| n/a

## Listing of Included Studies for Appendix I

Ackerman Z, Eliakim R, Stalnikowicz R, Rachmilewitz D. Role of small bowel biopsy in the endoscopic evaluation of adults with iron deficiency anemia. Am J Gastroenterol. (1996);91:2099-2102. [pmid: 8855729].
Addolorato G, Capristo E, Ghittoni G, Valeri C, Masciana R, Ancona C, Gasbarrini G. Anxiety but not depression decreases in coeliac patients after one-year gluten-free diet: a longitudinal study. Scand J Gastroenterol. (2001);36:502-506. [pmid: 11346203].
Agardh D, Nilsson A, Tuomi T, Lindberg B, Carlsson A K, Lernmark A, Ivarsson S-A. Prediction of silent celiac disease at diagnosis of childhood type 1 diabetes by tissue transglutaminase autoantibodies and HLA. Pediatr Diabetes. (2001);2:58-65. [pmid: 15016199].
Altuntas B, Kansu A, Ensari A, Girgin N. Celiac disease in Turkish short-statured children and the value of antigliadin antibody in diagnosis. Acta Paediatr Jpn. (1998);40:457-460. [pmid: 9821706].
Amin R, Murphy N, Edge J, Ahmed M L, Acerini C L, Dunger D B. A longitudinal study of the effects of a gluten-free diet on glycemic control and weight gain in subjects with type 1 diabetes and celiac disease. Diabetes Care. (2002);25:1117-1122. [pmid: 12087007].
Annibale B, Capurso G, Chistolini A, D'Ambra G, DiGiulio E, Monarca B, DelleFave G. Gastrointestinal causes of refractory iron deficiency anemia in patients without gastrointestinal symptoms. Am J Med. (2001);111:439-445. [pmid: 11690568].
Annibale B, Lahner E, Chistolini A, Gallucci C, Di Giulio E, Capurso G, Luana O, Monarca B, Delle F G. Endoscopic evaluation of the upper gastrointestinal tract is worthwhile in premenopausal women with iron-deficiency anaemia irrespective of menstrual flow. Scand J Gastroenterol. (2003);38:239-245. [pmid: 12737437].
Annibale B, Severi C, Chistolini A, Antonelli G, Lahner E, Marcheggiano A, Iannoni C, Monarca B, Delle F G. Efficacy of gluten-free diet alone on recovery from iron deficiency anemia in adult celiac patients. Am J Gastroenterol. (2001);96:132-137. [pmid: 11197242].
Anson O, Weizman Z, Zeevi N. Celiac disease: parental knowledge and attitudes of dietary compliance. Pediatrics. (1990);85:98-103. [pmid: 2296499].
Arato A, Korner A, Veres G, Dezsofi A, Ujpal I, Madacsy L. Frequency of coeliac disease in Hungarian children with type 1 diabetes mellitus. Eur J Pediatr. (2002);162:1-5. [pmid: 12486500].
Artan R. Antigliadin antibody measurement as a screening test for childhood coeliac disease. Int Med J. (1998);5:209-212.
Ascher H, Hahn-Zoric M, Hanson L A, Kilander A F, Nilsson L A, Tlaskalova H. Value of serologic markers for clinical diagnosis and population studies of coeliac disease. Scandinavian Journal of Gastroenterology. (1996);31:61-67. [pmid: 8927942].
Ascher H, Lanner A, Kristiansson B. A new laboratory kit for anti-gliadin IgA at diagnosis and follow-up of childhood celiac disease. Journal of Pediatric Gastroenterology and Nutrition. (1990);10:443-450. [pmid: 2358975].
Askling J, Linet M, Gridley G, Halstensen T S, Ekstrom K, Ekbom A. Cancer incidence in a population-based cohort of individuals hospitalized with celiac disease or dermatitis herpetiformis. Gastroenterology. (2002);123:1428-1435. [pmid: 12404215].
Bahia M, Rabello A, Brasileiro F G, Penna F J. Serum antigliadin antibody levels as a screening criterion before jejunal biopsy indication for celiac disease in a developing country. Brazilian Journal of Medical and Biological Research = Revista Brasileira De Pesquisas Medicas E Biologicas / Sociedade Brasileira De Biofisica …Et Al. (2001);34:1415-1420.
Bao F, Yu L, Babu S, Wang T, Hoffenberg E J, Rewers M, Eisenbarth G S. One third of HLA DQ2 homozygous patients with type 1 diabetes express celiac disease-associated transglutaminase autoantibodies. J Autoimmun. (1999);13:143-148. [pmid: 10441179].
Bardella M T, Fredella C, Prampolini L, Molteni N, Giunta A M, Bianchi P A. Body composition and dietary intakes in adult celiac disease patients consuming a strict gluten-free diet. Am J Clin Nutr. (2000);72:937-939. [pmid: 11010934].
Bardella M T, Molteni N, Cesana B, Baldassarri A R, Binanchi P A. IgA antigliadin antibodies, cellobiose/mannitol sugar test, and carotenemia in the diagnosis of and screening for celiac disease. Am J Gastroenterol. (1991);86:309-311. [pmid: 1900142].
Bardella M T, Molteni N, Quatrini M, Velio P, Ranzi T, Bianchi P A. Clinical, biochemical and histological abnormalities in adult celiac patients on gluten-free diet. Gastroenterol Clin Biol. (1985);9:787-789. [pmid: 4085741].
Bardella M T, Trovato C, Cesana B M, Pagliari C, Gebbia C, Peracchi M. Serological markers for coeliac disease: Is it time to change?. Dig Liver Dis. (2001);33:426-431. [pmid: 11529655].
Barera G, Bianchi C, Calisti L, Cerutti F, Dammacco F, Frezza E, Illeni M T, Mistura L, Pocecco M, Prisco F. Screening of diabetic children for coeliac disease with antigliadin antibodies and HLA typing. Arch Dis Child. (1991);66:491-494. [pmid: 2031607].
Barera G, Bonfanti R, Viscardi M, Bazzigaluppi E, Calori G, Meschi F, Bianchi C, Chiumello G. Occurrence of celiac disease after onset of type 1 diabetes: a 6-year prospective longitudinal study. Pediatrics. (2002);109:833-838. [pmid: 11986443].
Barera G, Mora S, Brambilla P, Ricotti A, Menni L, Beccio S, Bianchi C. Body composition in children with celiac disease and the effects of a gluten-free diet: a prospective case-control study. Am J Clin Nutr. (2000);72:71-75. [pmid: 10871563].
Bartholomeusz R C, Labrooy J T, Davidson G P, Hetzel P, Johnson R B, Shearman D J. Polymeric IgA antibody to gliadin in the serum of patients with coeliac disease. J Gastroenterol Hepatol. (1990);5:675-681. [pmid: 2129839].
Berger R, Schmidt G. Evaluation of six anti-gliadin antibody assays. Journal of Immunological Methods. (1996);191:77-86. [pmid: 8642204].
Biagi F, Pezzimenti D, Campanella J, Vadacca G B, Corazza G R. Endomysial and tissue transglutaminase antibodies in coeliac sera: a comparison not influenced by previous serological testing. Scandinavian Journal of Gastroenterology. (2001);36:955-958. [pmid: 11521986].
Bode S, Gudmand-Hoyer E. Evaluation of the gliadin antibody test for diagnosing coeliac disease. Scandinavian Journal of Gastroenterology. (1994);29:148-152. [pmid: 8171283].
Bode S, Gudmand-Hoyer E. Incidence and prevalence of adult coeliac disease within a defined geographic area in Denmark. Scand J Gastroenterol. (1996);31:694-699. [pmid: 8819220].
Bode S, Weile B, Krasilnikoff P A, Gudmand-Hoyer E. The diagnostic value of the gliadin antibody test in celiac disease in children: a prospective study. J Pediatr Gastroenterol Nutr. (1993);17:260-264. [pmid: 8271124].
Boersma B, Houwen R H J, Blum W F, van Doorn J, Wit J M. Catch-up growth and endocrine changes in childhood celiac disease. Endocrine changes during catch-up growth. Horm Res. (2002);58:57-65. [pmid: 12373016].
Bonamico M, Tiberti C, Picarelli A, Mariani P, Rossi D, Cipolletta E, Greco M, Tola M D, Sabbatella L, Carabba B, Magliocca F M, Strisciuglio P, Di Mario U. Radioimmunoassay to detect antitransglutaminase autoantibodies is the most sensitive and specific screening method for celiac disease. American Journal of Gastroenterology. (2001);96:1536-1540. [pmid: 11374695].
Book L, Zone J J, Neuhausen S L. Prevalence of celiac disease among relatives of sib pairs with celiac disease in U.S. families. Am J Gastroenterol. (2003);98:377-381. [pmid: 12591058].
Borch K, Grodzinsky E, Petersson F, Jonsson K-A, Mardh S, Valdimarsson T. Prevalence of coeliac disease and relations to Helicobacter pylori infection and duodenitis in a Swedish adult population sample: A histomorphological and serological survey. Inflammopharmacology. (2000);8:341-350.
Bottaro G, Volta U, Spina M, Rotolo N, Sciacca A, Musumeci S. Antibody pattern in childhood celiac disease. Journal of Pediatric Gastroenterology and Nutrition. (1997);24:559-562. [pmid: 9161952].
Burgin-Wolff A, Gaze H, Hadziselimovic F, Huber H, Lentze M J, Nussle D, Reymond-Berthet C. Antigliadin and antiendomysium antibody determination for coeliac disease. Arch Dis Child. (1991);66:941-947. [pmid: 1819255].
Calero P, Ribes-Koninckx C, Albiach V, Carles C, Ferrer J. IgA antigliadin antibodies as a screening method for nonovert celiac disease in children with insulin-dependent diabetes mellitus. J Pediatr Gastroenterol Nutr. (1996);23:29-33. [pmid: 8811520].
Carlsson A K, Axelsson I E, Borulf S K, Bredberg A C, Ivarsson S A. Serological screening for celiac disease in healthy 2.5-year-old children in Sweden. Pediatrics. (2001);107:42-45. [pmid: 11134432].
Carroccio A, Iacono G, D'Amico D, Cavataio F, Teresi S, Caruso C, Di Prima L, Colombo A, D'Arpa F, Florena A, Notarbartolo A, Montalto G. Production of anti-endomysial antibodies in cultured duodenal mucosa: usefulness in coeliac disease diagnosis. Scandinavian Journal of Gastroenterology. (2002);37:32-38. [pmid: 11843032].
Carroccio A, Iacono G, Montalto G, Cavataio F, Soresi M, Kazmierska I, Notarbartolo A. Immunologic and absorptive tests in celiac disease: can they replace intestinal biopsies?. Scandinavian Journal of Gastroenterology. (1993);28:673-676. [pmid: 8210980].
Carroccio A, Vitale G, Di Prima L, Chifari N, Napoli S, La Russa C, Gulotta G, Averna M R, Montalto G, Mansueto S, Notarbartolo A. Comparison of anti-transglutaminase ELISAs and an anti-endomysial antibody assay in the diagnosis of celiac disease: a prospective study. Clin Chem. (2002);48:1546-1550. [pmid: 12194932].
Cataldo F, Lio D, Marino V, Picarelli A, Ventura A, Corazza G R. IgG(1) antiendomysium and IgG antitissue transglutaminase (anti-tTG) antibodies in coeliac patients with selective IgA deficiency Working Groups on Celiac Disease of SIGEP and Club del Tenue. Gut. (2000);47:366-369. [pmid: 10940273]. [pmcid: 1728054].
Catassi C, Fabiani E, Ratsch I M, et al. The coeliac iceberg in Italy. A multicentre antigliadin antibodies screening for coeliac disease in school-age subjects. Acta Paediatr. (1996);412:29-35.
Catassi C, Fanciulli G, D'Appello A R, El Asmar R, Rondina C, Fabiani E, Bearzi I, Coppa G V. Antiendomysium versus antigliadin antibodies in screening the general population for coeliac disease. Scand J Gastroenterol. (2000);35:732-736. [pmid: 10972177].
Chan A W, Butzner J D, McKenna R, Fritzler M J. Tissue transglutaminase enzyme-linked immunosorbent assay as a screening test for celiac disease in pediatric patients. Pediatrics. (2001);107:E8. [pmid: 11134472].
Chartrand L J, Agulnik J, Vanounou T, Russo P A, Baehler P, Seidman E G. Effectiveness of antigliadin antibodies as a screening test for celiac disease in children. CMAJ. (1997);157:527-533. [pmid: 9294391]. [pmcid: 1227966].
Chirdo F G, Rumbo M, Carabajal P, Castagnino N, Mavromatopulos E, Cirincione V, Anon M C, Fossati C A. Analysis of anti-gliadin antibodies by immunoblot analysis and enzyme-linked immunosorbent assay using gliadin fractions as antigens. Journal of Pediatric Gastroenterology and Nutrition. (1999);29:171-177. [pmid: 10435654].
Chirdo F G, Rumbo M, Carabajal P, Mavromatopulos E, Castagnino N, Anon M C, Fossati C A. Determination of anti-omega-gliadin antibodies in serologic tests for coeliac disease. Scandinavian Journal of Gastroenterology. (2000);35:508-516. [pmid: 10868454].
Ciacci C, Cirillo M, Auriemma G, Di Dato G, Sabbatini F, Mazzacca G. Celiac disease and pregnancy outcome. Am J Gastroenterol. (1996);91:718-722. [pmid: 8677936].
Collin P, Reunala T, Rasmussen M, Kyronpalo S, Pehkonen E, Laippala P, Maki M. High incidence and prevalence of adult coeliac disease. Augmented diagnostic approach. Scand J Gastroenterol. (1997);32:1129-1133. [pmid: 9399394].
Collin P, Syrjanen J, Partanen J, Pasternack A, Kaukinen K, Mustonen J. Celiac disease and HLA DQ in patients with IgA nephropathy. American Journal of Gastroenterology. (2002);97:2572-2576. [pmid: 12385441].
Corazza G R, Andreani M L, Biagi F, Corrao G, Pretolani S, Giulianelli G, Ghironzi G, Gasbarrini G. The smaller size of the ‘coeliac iceberg’ in adults. Scand J Gastroenterol. (1997);32:917-919. [pmid: 9299671].
Corrao G, Corazza G R, Bagnardi V, Brusco G, Ciacci C, Cottone M, Sategna G C, Usai P, Cesari P, Pelli M A, Loperfido S, Volta U, Calabro A, Certo M. Mortality in patients with coeliac disease and their relatives: a cohort study. Lancet. (2001);358:356-361. [pmid: 11502314].
Corrao G, Usai P, Galatola G, Ansaldi N, Meini A, Pelli M A, Castellucci G, Corazza G R. Estimating the incidence of coeliac disease with capture-recapture methods within four geographic areas in Italy. J Epidemiol Community Health. (1996);50:299-305. [pmid: 8935462].
Cottone M, Termini A, Oliva L, Magliocco A, Marrone C, Orlando A, Pinzone F, Di Mitri R, Rosselli M, Rizzo A, Pagliaro L. Mortality and causes of death in celiac disease in a Mediterranean area. Dig Dis Sci. (1999);44:2538-2541. [pmid: 10630509].
Cronin C C, Feighery A, Ferriss J B, Liddy C, Shanahan F, Feighery C. High prevalence of celiac disease among patients with insulin-dependent (type I) diabetes mellitus. Am J Gastroenterol. (1997);92:2210-2212. [pmid: 9399754].
Csizmadia C G D S, Mearin M L, Von Blomberg B M E, Brand R, Verloove-Vanhorick S P. An iceberg of childhood coeliac disease in the Netherlands. Lancet. (1999);353:813-814. [pmid: 10459972].
Dahele A, Kingstone K, Bode J, Anderson D, Ghosh S. Anti-endomysial antibody negative celiac disease: does additional serological testing help?. Digestive Diseases and Sciences. (2001);46:214-221. [pmid: 11270789].
Dahele A V, Aldhous M C, Humphreys K, Ghosh S. Serum IgA tissue transglutaminase antibodies in coeliac disease and other gastrointestinal diseases. Q J Med. (2001);94:195-205.
Day A S, Cook H B, Whitehead M, Abbott G D. Anti-endomysial and anti-gliadin antibodies in screening for coeliac disease in children at greater risk of developing coeliac disease. N Z Med J. (2000);113:412-413. [pmid: 11127356].
De Block C E, De L I, Vertommen J J, Rooman R P, Du C M V, Van Campenhout C M, Weyler J J, Winnock F, Van Autreve J, Gorus F K. Beta-cell, thyroid, gastric, adrenal and coeliac autoimmunity and HLA-DQ types in type 1 diabetes. Clin Exp Immunol. (2001);126:236-241. [pmid: 11703366]. [pmcid: 1906197].
De Vitis I, Ghirlanda G, Gasbarrini G. Prevalence of coeliac disease in type I diabetes: a multicentre study. Acta Paediatr. (1996);412:56-57.
Delco F, El Serag H B, Sonnenberg A. Celiac sprue among US military veterans: associated disorders and clinical manifestations. Dig Dis Sci. (1999);44:966-972. [pmid: 10235605].
Di Leo M, Weisz G, Ansaldi B N. Serum and salivary antiendomysium antibodies in the screening of coeliac disease. Panminerva Medica. (1999);41:68-71. [pmid: 10230262].
Dickey W, Hughes D F, McMillan S A. Disappearance of endomysial antibodies in treated celiac disease does not indicate histological recovery. Am J Gastroenterol. (2000);95:712-714. [pmid: 10710062].
Dickey W, Kenny B D, McMillan S A, Porter K G, McConnell J B. Gastric as well as duodenal biopsies may be useful in the investigation of iron deficiency anaemia. Scand J Gastroenterol. (1997);32:469-472. [pmid: 9175209].
Dickey W, McMillan S A, Bharucha C, Porter K G. Antigliadin antibodies in blood donors in Northern Ireland. Eur J Gastroenterol Hepatol. (1992);4:739-741.
Dickey W, McMillan S A, Hughes D F. Sensitivity of serum tissue transglutaminase antibodies for endomysial antibody positive and negative coeliac disease. Scandinavian Journal of Gastroenterology. (2001);36:511-514. [pmid: 11346205].
Fabiani E, Catassi C. The serum IgA class anti-tissue transglutaminase antibodies in the diagnosis and follow up of coeliac disease. Results of an international multi-centre study. International Working Group on Eu-tTG. Eur J Gastroenterol Hepatol. (2001);13:659-665. [pmid: 11434591].
Fabiani E, Catassi C, Villari A, Gismondi P, Pierdomenico R, Ratsch I M, Coppa G V, Giorgi P L. Dietary compliance in screening-detected coeliac disease adolescents. Acta Paediatr. (1996);412:65-67.
Fabiani E, Taccari L M, Ratsch I M, Di Giuseppe S, Coppa G V, Catassi C. Compliance with gluten-free diet in adolescents with screening-detected celiac disease: a 5-year follow-up study. J Pediatr. (2000);136:841-843. [pmid: 10839888].
Falth-Magnusson K, Jansson G, Stenhammar L, Magnusson K E. Serum food antibodies analyzed by enzyme-linked immunosorbent assay (ELISA) and diffusion-in-gel (DIG)-ELISA methods in children with and without celiac disease. Journal of Pediatric Gastroenterology and Nutrition. (1994);18:56-62. [pmid: 8126619].
Farre C, Humbert P, Vilar P, Varea V, Aldeguer X, Carnicer J, Carballo M, Gassull MA (1999b Serological markers and HLA-DQ2 haplotype among first-degree relatives of celiac patients. Catalonian Coeliac Disease Study Group. Dig Dis Sci 44: 2344–2349
Fasano A, Berti I, Gerarduzzi T, Not T, Colletti R B, Drago S, Elitsur Y, Green P H R, Guandalini S, Hill I D, Pietzak M, Ventura A, Thorpe M, Kryszak D, Fornaroli F, Wasserman S S, Murray J A, Horvath K. Prevalence of celiac disease in at-risk and not-at-risk groups in the United States: a large multicenter study. Arch Intern Med. (2003);163:286-292. [pmid: 12578508].
Fickling W E, McFarlane X A, Bhalla A K, Robertson D A. The clinical impact of metabolic bone disease in coeliac disease. Postgrad. Med J. (2001);77:33-36.
Fitzpatrick K P, Sherman P M, Ipp M, Saunders N, Macarthur C. Screening for celiac disease in children with recurrent abdominal pain. J Pediatr Gastroenterol Nutr. (2001);33:250-252. [pmid: 11593117].
Fotoulaki M, Nousia-Arvanitakis S, Augoustidou-Savvopoulou P, Kanakoudi-Tsakalides F, Zaramboukas T, Vlachonikolis J. Clinical application of immunological markers as monitoring tests in celiac disease. Dig Dis Sci. (1999);44:2133-2138. [pmid: 10548368].
Fraser-Reynolds K A, Butzner J D, Stephure D K, Trussell R A, Scott R B. Use of immunoglobulin A-antiendomysial antibody to screen for celiac disease in North American children with type 1 diabetes. Diabetes Care. (1998);21:1985-1989. [pmid: 9802755].
Gillett H R, Freeman H J. Comparison of IgA endomysium antibody and IgA tissue transglutaminase antibody in celiac disease. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. (2000);14:668-671.
Gillett P M, Gillett H R, Israel D M, Metzger D L, Stewart L, Chanoine J P, Freeman H J. High prevalence of celiac disease in patients with type 1 diabetes detected by antibodies to endomysium and tissue transglutaminase. Can J Gastroenterol. (2001);15:297-301. [pmid: 11381296].
Gonczi J, Skerritt J H, Mitchell J D. A reliable screening test for coeliac disease: enzyme-linked immunosorbent assay to detect anti-gliadin antibodies in serum. Australian and New Zealand Journal of Medicine. (1991);21:723-731. [pmid: 1759921].
Gonzalez D, Sugai E, Gomez J C, Oliveri M B, Gomez A C, Vega E, Bagur A, Mazure R, Maurino E, Bai J C, Mautalen C. Is it necessary to screen for celiac disease in postmenopausal osteoporotic women?. Calcif Tissue Int. (2002);71:141-144. [pmid: 12200648].
Greco L, Mayer M, Ciccarelli G, Troncone R, Auricchio S. Compliance to a gluten-free diet in adolescents, or “what do 300 coeliac adolescents eat every day?”. Ital J Gastroenterol Hepatol. (1997);29:305-310. [pmid: 9476181].
Green P H, Shane E, Rotterdam H, Forde K A, Grossbard L. Significance of unsuspected celiac disease detected at endoscopy. Gastroenterol Int. (2000);51:60-65.
Green P H R, Fleischauer A T, Bhagat G, Goyal R, Jabri B, Neugut A I. Risk of malignancy in patients with celiac disease. Am J Med. (2003);115:191-195. [pmid: 12935825].
Grodzinsky E. Screening for coeliac disease in apparently healthy blood donors. Acta Paediatr. (1996);412:36-38.
Hallstrom O. Comparison of IgA-class reticulin and endomysium antibodies in coeliac disease and dermatitis herpetiformis. Gut. (1989);30:1225-1232. [pmid: 2806989]. [pmcid: 1434235].
Hansen D, Bennedbaek F N, Hansen L K, Hoier-Madsen M, Hegedu L S, Jacobsen B B, Husby S. High prevalence of coeliac disease in Danish children with type I diabetes mellitus. Acta Paediatr. (2001);90:1238-1243. [pmid: 11808892].
Hansson T, Dahlbom I, Hall J, Holtz A, Elfman L, Dannaeus A, Klareskog L. Antibody reactivity against human and guinea pig tissue transglutaminase in children with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. (2000);30:379-384. [pmid: 10776947].
Hawkes N D, Swift G L, Smith P M, Jenkins H R. Incidence and presentation of coeliac disease in South Glamorgan. Eur J Gastroenterol Hepatol. (2000);12:345-349. [pmid: 10750656].
Hill I, Fasano A, Schwartz R, Counts D, Glock M, Horvath K. The prevalence of celiac disease in at-risk groups of children in the United States. J Pediatr. (2000);136:86-90. [pmid: 10636980].
Hin H, Bird G, Fisher P, Mahy N, Jewell D. Coeliac disease in primary care: case finding study. BMJ. (1999);318:164-167. [pmid: 9888912]. [pmcid: 27697].
Hoffenberg E J, MacKenzie T, Barriga K J, Eisenbarth G S, Bao F, Haas J E, Erlich H, Bugawan T L, Sokol R J, Taki I, Norris J M, Rewers M. A prospective study of the incidence of childhood celiac disease. J Pediatr. (2003);143:308-314. [pmid: 14517510].
Hogberg L, Falth-Magnusson K, Grodzinsky E, Stenhammar L. Familial prevalence of coeliac disease: A twenty-year follow-up study. Scand J Gastroenterol. (2003);38:61-65. [pmid: 12608466].
Hogberg L, Grodzinsky E, Stenhammar L. Better dietary compliance in patients with coeliac disease diagnosed in early childhood. Scand J Gastroenterol. (2003);38:751-754. [pmid: 12889562].
Holm K H. Correlation of HLA-DR alleles to jejunal mucosal morphology in healthy first-degree relatives of coeliac disease patients. Eur J Gastroenterol Hepatol. (1993);5:35-39.
Holmes G K, Prior P, Lane M R, Pope D, Allan R N. Malignancy in coeliac disease--effect of a gluten free diet. Gut. (1989);30:333-338. [pmid: 2707633]. [pmcid: 1378455].
Hovdenak N, Hovlid E, Aksnes L, Fluge G, Erichsen M M, Eide J. High prevalence of asymptomatic coeliac disease in Norway: a study of blood donors. Eur J Gastroenterol Hepatol. (1999);11:185-187. [pmid: 10102231].
Howard M R, Turnbull A J, Morley P, Hollier P, Webb R, Clarke A. A prospective study of the prevalence of undiagnosed coeliac disease in laboratory defined iron and folate deficiency. J Clinl Path. (2002);55:754-757.
Iltanen S, Holm K, Partanen J, Laippala P, Maki M. Increased density of jejunal gammadelta+ T cells in patients having normal mucosa--marker of operative autoimmune mechanisms?. Autoimmunity. (1999);29:179-187. [pmid: 10680751].
Iltanen S, Rantala I, Laippala P, Holm K, Partanen J, Maki M. Expression of HSP-65 in jejunal epithelial cells in patients clinically suspected of coeliac disease. Autoimmunity. (1999);31:125-132. [pmid: 10680751].
Ivarsson A, Persson L A, Juto P, Peltonen M, Suhr O, Hernell O. High prevalence of undiagnosed coeliac disease in adults: a Swedish population-based study. J Intern Med. (1999);245:63-68. [pmid: 10095818].
Ivarsson A, Persson L A, Nystrom L, Hernell O. The Swedish coeliac disease epidemic with a prevailing twofold higher risk in girls compared to boys may reflect gender specific risk factors. Eur J Epidemiol. (2003);18:677-684. [pmid: 12952142].
Jackson P T, Glasgow J F, Thom R. Parents' understanding of coeliac disease and diet. Arch Dis Child. (1985);60:672-674. [pmid: 4026368].
Jaeger C, Hatziagelaki E, Petzoldt R, Bretzel R G. Comparative analysis of organ-specific autoantibodies and celiac disease--associated antibodies in type 1 diabetic patients, their first-degree relatives, and healthy control subjects. Diabetes Care. (2001);24:27-32. [pmid: 11194235].
Jansen Th T L A, Mulder C J J, Karssen P H Z, Wagenaar C G J. Epidemiological survey of the Dutch Coeliac Disease Society: An update 1992. Eur J Gastroenterol Hepatol. (1993);5:73-78.
Johnston S D, Watson R G, McMillan S A, Sloan J, Love A H. Coeliac disease detected by screening is not silent--simply unrecognized. Q J Med. (1998);91:853-860.
Kaukinen K, Collin P, Mykkanen A H, Partanen J, Maki M, Salmi J. Celiac disease and autoimmune endocrinologic disorders. Dig Dis Sci. (1999);44:1428-1433. [pmid: 10489930].
Kaukinen K, Turjanmaa K, Maki M, Partanen J, Venalainen R, Reunala T, Collin P. Intolerance to cereals is not specific for coeliac disease. Scandinavian Journal of Gastroenterology. (2000);35:942-946. [pmid: 11063153].
Kaukinen K, Sulkanen S, Maki M, Collin P. IgA-class transglutaminase antibodies in evaluating the efficacy of gluten-free diet in coeliac disease. Eur J Gastroenterol Hepatol. (2002);14:311-315. [pmid: 11953698].
Kemppainen T A, Kosma V M, Janatuinen E K, Julkunen R J, Pikkarainen P H, Uusitupa M I. Nutritional status of newly diagnosed celiac disease patients before and after the institution of a celiac disease diet--association with the grade of mucosal villous atrophy. Am J Clin Nutr. (1998);67:482-487. [pmid: 9497194].
Kepczyk T, Kadakia S C. Prospective evaluation of gastrointestinal tract in patients with iron-deficiency anemia. Dig Dis Sci. (1995);40:1283-1289. [pmid: 7781448].
Kolho K L, Farkkila M A, Savilahti E. Undiagnosed coeliac disease is common in Finnish adults. Scand J Gastroenterol. (1998);33:1280-1283. [pmid: 9930391].
Kolho K L, Savilahti E. IgA endomysium antibodies on human umbilical cord: an excellent diagnostic tool for celiac disease in childhood. Journal of Pediatric Gastroenterology and Nutrition. (1997);24:563-567. [pmid: 9161953].
Kordonouri O, Dieterich W, Schuppan D, Webert G, Muller C, Sarioglu N, Becker M, Danne T. Autoantibodies to tissue transglutaminase are sensitive serological parameters for detecting silent coeliac disease in patients with Type 1 diabetes mellitus. Diabet Med. (2000);17:441-444. [pmid: 10975212].
Korponay-Szabo I, Kovacs J, Lorincz M, Torok E, Goracz G. Families with multiple cases of gluten-sensitive enteropathy. Z Gastroenterol. (1998);36:553-558. [pmid: 9738302].
Kotze L M, Utiyama S R, Nisihara R M, Zeni M P, de Sena M G, Amarante H M. Antiendomysium antibodies in Brazilian patients with celiac disease and their first-degree relatives. Arq Gastroenterol. (2001);38:94-103. [pmid: 11793949].
Kumar V, Lerner A, Valeski J E, Beutner E H, Chorzelski T P, Rossi T. Endomysial antibodies in the diagnosis of celiac disease and the effect of gluten on antibody titers. Immunological Investigations. (1989);18:533-544. [pmid: 2499536].
Ladinser B, Rossipal E, Pittschieler K. Endomysium antibodies in coeliac disease: an improved method. Gut. (1994);35:776-778. [pmid: 8020804]. [pmcid: 1374877].
Lamontagne P, West G E, Galibois I. Quebecers with celiac disease: analysis of dietary problems. Canadian Journal of Dietetic Practice and Research - a Publication of Dietitians of Canada = Revue Canadienne De La Pratique Et De La Recherche En Dietetique - Une Publication Des Dietetistes Du C. (2001);62:175-181.
Lampasona V, Bonfanti R, Bazzigaluppi E, Venerando A, Chiumello G, Bosi E, Bonifacio E. Antibodies to tissue transglutaminase C in type I diabetes. Diabetologia. (1999);42:1195-1198. [pmid: 10525659].
Lee S K, Lo W, Memeo L, Rotterdam H, Green Peter H R. Duodenal histology in patients with celiac disease after treatment with a gluten-free diet. Gastrointest Endosc. (2003);57:187-191. [pmid: 12556782].
Lerner A, Kumar V, Iancu T C. Immunological diagnosis of childhood coeliac disease: comparison between antigliadin, antireticulin and antiendomysial antibodies. Clinical and Experimental Immunology. (1994);95:78-82. [pmid: 8287612]. [pmcid: 1534627].
Li Voon Chong J S W, Leong K S, Wallymahmed M, Sturgess R, MacFarlane I A. Is coeliac disease more prevalent in young adults with coexisting Type 1 diabetes mellitus and autoimmune thyroid disease compared with those with Type 1 diabetes mellitus alone?. Diabet Med. (2002);19:334-337. [pmid: 11943007].
Lindberg T, Nilsson L A, Borulf S, Cavell B, Fallstrom S P, Jansson U, Stenhammar L, Stintzing G. Serum IgA and IgG gliadin antibodies and small intestinal mucosal damage in children. Journal of Pediatric Gastroenterology and Nutrition. (1985);4:917-922. [pmid: 4067780].
Lindh E, Ljunghall S, Larsson K, Lavo B. Screening for antibodies against gliadin in patients with osteoporosis. J Intern Med. (1992);231:403-406. [pmid: 1588266].
Lindquist B L, Rogozinski T, Moi H, Danielsson D, Olcen P. Endomysium and gliadin IgA antibodies in children with coeliac disease. Scandinavian Journal of Gastroenterology. (1994);29:452-456. [pmid: 8036461].
Ljungman G, Myrdal U. Compliance in teenagers with coeliac disease--a Swedish follow-up study. Acta Paediatr. (1993);82:235-238. [pmid: 8495075].
Logan R F, Rifkind E A, Turner I D, Ferguson A. Mortality in celiac disease. Gastroenterology. (1989);97:265-271. [pmid: 2744350].
Lopez-Rodriguez M J, Canal Macias M L, Lavado Garcia J M, Sanchez B M, Robledo A P, Pedrera Zamorano J D. Epidemiological changes in diagnosed coeliac disease in a population of Spanish children. Acta Paediatr. (2003);92:165-169. [pmid: 12710641].
Lorini R, Scotta M S, Cortona L, Avanzini M A, Vitali L, De Giacomo C, Scaramuzza A, Severi F. Celiac disease and type I (insulin-dependent) diabetes mellitus in childhood: follow-up study. J Diabetes Complications. (1996);10:154-159. [pmid: 8807465].
Magazzu G, Bottaro G, Cataldo F, Iacono G, Di Donato F, Patane R, Cavataio F, Maltese I, Romano C, Arco A. Increasing incidence of childhood celiac disease in Sicily: results of a multicenter study. Acta Paediatr. (1994);83:1065-1069. [pmid: 7841706].
Maki M, Holm K. Incidence and prevalence of coeliac disease in Tampere. Coeliac disease is not disappearing. Acta Paediatrica Scandinavica. (1990);79:980-982. [pmid: 2264477].
Maki M, Holm K, Lipsanen V, Hallstrom O, Viander M, Collin P, Savilahti E, Koskimies S. Serological markers and HLA genes among healthy first-degree relatives of patients with coeliac disease. Lancet. (1991);338:1350-1353. [pmid: 1682735].
Maki M, Mustalahti K, Kokkonen J, Kulmala P, Haapalahti M, Karttunen T, Ilonen J, Laurila K, Dahlbom I, Hansson T, Hopfl P, Knip M. Prevalence of Celiac disease among children in Finland. New Engl J Med. (2003);348:2517-2524. [pmid: 12815137].
Martini S, Mengozzi G, Aimo G, Giorda L, Pagni R, Guidetti C S. Comparative evaluation of serologic tests for celiac disease diagnosis and follow-up. Clin Chem. (2002);48:960-963. [pmid: 12029021].
Mather K J, Meddings J B, Beck P L, Scott R B, Hanley D A. Prevalence of IgA-antiendomysial antibody in asymptomatic low bone mineral density. Am J Gastroenterol. (2001);96:120-125. [pmid: 11197240].
Mazzetti dP, Giorgetti G M, Gregori M, De Simone M, Leonardi C, Barletta P A, Ricciardi M M, Sandri G. Subclinical coeliac disease. Ital J Gastroenterol. (1992);24:352-354. [pmid: 1515663].
McIntyre A S, Long R G. Prospective survey of investigations in outpatients referred with iron deficiency anaemia. Gut. (1993);34:1102-1107. [pmid: 8174963]. [pmcid: 1374363].
McMillan S A, Haughton D J, Biggart J D, Edgar J D, Porter K G, McNeill T A. Predictive value for coeliac disease of antibodies to gliadin, endomysium, and jejunum in patients attending for jejunal biopsy. Bmj (Clinical Research Ed.). (1991);303:1163-1165. [pmid: 1747612].
McNicholl B, Egan-Mitchell B, Stevens F, Keane R, Baker S, McCarthy C F, Fottrell P F. Mucosal recovery in treated childhood celiac disease (gluten-sensitive enteropathy). J Pediatr. (1976);89:418-424. [pmid: 956966].
Meini A, Pillan N M, Villanacci V, Monafo V, Ugazio A G, Plebani A. Prevalence and diagnosis of celiac disease in IgA-deficient children. Annals of Allergy, Asthma & Immunology - Official Publication of the American College of Allergy, Asthma, & Immunology. (1996);77:333-336. [pmid: 8885812].
Moreno M L, Vazquez H, Mazure R, Smecuol E, Niveloni S, Pedreira S, Sugai E, Maurino E, Gomez J C, Bai J C. Stratification of bone fracture risk in patients with celiac disease. Clin Gastroenterol. Hepatol. (2004);2:127-134.
Mustalahti K, Sulkanen S, Holopainen P, Laurila K, Collin P, Partanen J, Maki M. Coeliac disease among healthy members of multiple case coeliac disease families. Scand J Gastroenterol. (2002);37:161-165. [pmid: 11843051].
Nielsen O H, Jacobsen O, Pedersen E R, Rasmussen S N, Petri M, Laulund S, Jarnum S. Non-tropical sprue. Malignant diseases and mortality rate. Scand J Gastroenterol. (1985);20:13-18. [pmid: 3992161].
Not T, Horvath K, Hill I D, Partanen J, Hammed A, Magazzu G, Fasano A. Celiac disease risk in the USA: high prevalence of antiendomysium antibodies in healthy blood donors. Scand J Gastroenterol. (1998);33:494-498. [pmid: 9648988].
Nuti R, Martini G, Valenti R, Giovani S, Salvadori S, Avanzati A. Prevalence of undiagnosed coeliac syndrome in osteoporotic women. J Intern Med. (2001);250:361-366. [pmid: 11576323].
Oxentenko A S, Grisolano S W, Murray J A, Burgart L J, Dierkhising R A, Alexander J A. The insensitivity of endoscopic markers in celiac disease. Am J Gastroenterol. (2002);97:933-938. [pmid: 12003429].
Pacht A, Sinai N, Hornstein L, Kumar V, Ish-Shalom N, Lerner A. The diagnostic reliability of anti-endomysial antibody in celiac disease: the north Israel experience. Isr J Med Sci. (1995);31:218-220. [pmid: 7721558].
Page S R, Lloyd C A, Hill P G, Peacock I, Holmes G K. The prevalence of coeliac disease in adult diabetes mellitus. Q J Med. (1994);87:631-637.
Picarelli A, Sabbatella L, Di Tola M, Gabrielli F, Greco R, Di Cello T, Mastracchio A, Anania M C. Celiac disease diagnosis in misdiagnosed children. Pediatric Research. (2000);48:590-592. [pmid: 11044476].
Pittschieler K, Gentili L, Niederhofer H. Onset of coeliac disease: A prospective longitudinal study. Acta Paediatr Int J Paediatr. (2003);92:1149-1152.
Pittschieler K, Ladinser B. Coeliac disease: screened by a new strategy. Acta Paediatr. (1996);412:42-45.
Poddar U, Thapa B R, Nain C K, Prasad A, ingh K. Celiac disease in India: are they true cases of celiac disease?. J Pediatr Gastroenterol Nutr. (2002);35:508-512. [pmid: 12394375].
Polvi A, Eland C, Koskimies S, Maki M, Partanen J. HLA DQ and DP in Finnish families with celiac disease. Eur J Immunogenet. (1996);23:221-234. [pmid: 8803535].
Ransford Rupert A J, Hayes M, Palmer M, Hall M J. A controlled, prospective screening study of celiac disease presenting as iron deficiency anemia. J Clin Gastroenterol. (2002);35:228-233. [pmid: 12192198].
Rea F, Polito C, Marotta A, Di Toro A, Iovene A, Collini R, Rea L, Sessa G. Restoration of body composition in celiac children after one year of gluten-free diet. J Pediatr Gastroenterol Nutr. (1996);23:408-412. [pmid: 8956176].
Rensch M J, Merenich J A, Lieberman M, Long B D, Davis D R, McNally P R. Gluten-sensitive enteropathy in patients with insulin-dependent diabetes mellitus. Ann Intern Med. (1996);124:564-567. [pmid: 8597319].
Rich E J, Christie D L. Anti-gliadin antibody panel and xylose absorption test in screening for celiac disease. Journal of Pediatric Gastroenterology and Nutrition. (1990);10:174-178. [pmid: 2182821].
Riestra S, Fernandez E, Rodrigo L, Garcia S, Ocio G. Prevalence of Coeliac disease in the general population of northern Spain. Strategies of serologic screening. Scand J Gastroenterol. (2000);35:398-402. [pmid: 10831263].
Robinson D C, Watson A J, Wyatt E H, Marks J M, Roberts D F. Incidence of small-intestinal mucosal abnormalities and of clinical coeliac disease in the relatives of children with coeliac disease. Gut. (1971);12:789-793. [pmid: 5123275]. [pmcid: 1411884].
Roldan M B, Barrio R, Roy G, Parra C, Alonso M, Yturriaga R, Camarero C. Diagnostic value of serological markers for celiac disease in diabetic children and adolescents. J Pediatr Endocrinol Metab. (1998);11:751-756. [pmid: 9829231].
Rolles C J, Myint T O, Sin W K, Anderson M. Proceedings: Family study of coeliac disease. Gut. (1974);15:827. [pmid: 4434938].
Rossi T M, Albini C H, Kumar V. Incidence of celiac disease identified by the presence of serum endomysial antibodies in children with chronic diarrhea, short stature, or insulin-dependent diabetes mellitus. J Pediatr. (1993);123:262-264. [pmid: 8345423].
Rostami K, Mulder C J, van Overbeek F M, Kerckhaert J, Meijer J W, von Blomberg M B, Heymans H S. Should relatives of coeliacs with mild clinical complaints undergo a small-bowel biopsy despite negative serology?. Eur J Gastroenterol Hepatol. (2000);12:51-55. [pmid: 10656210].
Rostami K, Mulder C J, Werre J M, van Beukelen F R, Kerchhaert J, Crusius J B, Pena A S, Willekens F L, Meijer J W. High prevalence of celiac disease in apparently healthy blood donors suggests a high prevalence of undiagnosed celiac disease in the Dutch population. Scand J Gastroenterol. (1999);34:276-279. [pmid: 10232872].
Russo P A, Chartrand L J, Seidman E. Comparative analysis of serologic screening tests for the initial diagnosis of celiac disease. Pediatrics. (1999);104:75-78. [pmid: 10390263].
Rutz R, Ritzler E, Fierz W, Herzog D. Prevalence of asymptomatic celiac disease in adolescents of eastern Switzerland. Swiss Med Wkly. (2002);132:43-47. [pmid: 11953905].
Sacchetti L, Calcagno G, Ferrajolo A, Sarrantonio C, Troncone R, Micillo M, Auricchio S, Salvatore F. Discrimination between celiac and other gastrointestinal disorders in childhood by rapid human lymphocyte antigen typing. Clinical Chemistry. (1998);44:1755-1757. [pmid: 9702970].
Salmaso C, Ocmant A, Pesce G, Altrinetti V, Montagna P, Descalzi D, Martino S, Bagnasco M, Mascart F. Comparison of ELISA for tissue transglutaminase autoantibodies with antiendomysium antibodies in pediatric and adult patients with celiac disease. Allergy. (2001);56:544-547. [pmid: 11421901].
Sanders D S, Patel D, Stephenson T J, Ward A M, McCloskey E V, Hadjivassiliou M, Lobo A J. A primary care cross-sectional study of undiagnosed adult coeliac disease. Eur J Gastroenterol Hepatol. (2003);15:407-413. [pmid: 12655262].
Sategna-Guidetti C, Grosso S. Changing pattern in adult coeliac disease: A 24-year survey. Eur J Gastroenterol Hepatol. (1994);6:15-19.
Sategna-Guidetti C, Grosso S, Bruno M, Grosso S B. Comparison of serum anti-gliadin, anti-endomysium, and anti-jejunum antibodies in adult celiac sprue. Journal of Clinical Gastroenterology. (1995);20:17-21. [pmid: 7884170].
Sategna-Guidetti C, Grosso S, Bruno M, Grosso S B. Reliability of immunologic markers of celiac sprue in the assessment of mucosal recovery after gluten withdrawal. J Clin Gastroenterol. (1996);23:101-104. [pmid: 8877634].
Sategna-Guidetti C, Volta U, Ciacci C, Usai P, Carlino A, De Franceschi L, Camera A, Pelli A, Brossa C. Prevalence of thyroid disorders in untreated adult celiac disease patients and effect of gluten withdrawal: an Italian multicenter study. Am J Gastroenterol. (2001);96:751-757. [pmid: 11280546].
Saukkonen T, Savilahti E, Reijonen H, Ilonen J, Tuomilehto-Wolf E, Akerblom H K. Coeliac disease: frequent occurrence after clinical onset of insulin-dependent diabetes mellitus. Childhood Diabetes in Finland Study Group. Diabet Med. (1996);13:464-470. [pmid: 8737029].
Saukkonen T, Vaisanen S, Akerblom H K, Savilahti E. Coeliac disease in children and adolescents with type 1 diabetes: a study of growth, glycaemic control, and experiences of families. Acta Paediatr. (2002);91:297-302. [pmid: 12022302].
Sblattero D, Berti I, Trevisiol C, Marzari R, Tommasini A, Bradbury A, Fasano A, Ventura A, Not T. Human recombinant tissue transglutaminase ELISA: an innovative diagnostic assay for celiac disease. American Journal of Gastroenterology. (2000);95:1253-1257. [pmid: 10811336].
Scalici C, Manzoni D, Licastro G, Varia F, Di Prima L, Vitali R. Reliability of EMA assay in the evaluation of gluten-free diet compliance in celiac patients during follow-up. Acta Med Mediterr. (2003);19:67-69.
Schober E, Bittmann B, Granditsch G, Huber W D, Huppe A, Jager A, Oberhuber G, Rami B, Reichel G. Screening by anti-endomysium antibody for celiac disease in diabetic children and adolescents in Austria. J Pediatr Gastroenterol Nutr. (2000);30:391-396. [pmid: 10776949].
Selby W S, Gallagher N D. Malignancy in a 19-year experience of adult celiac disease. Dig Dis Sci. (1979);24:684-688. [pmid: 487922].
Selby W S, Painter D, Collins A, Faulkner-Hogg K B, Loblay R H. Persistent mucosal abnormalities in coeliac disease are not related to the ingestion of trace amounts of gluten. Scand J Gastroenterol. (1999);34:909-914. [pmid: 10522611].
Sigurs N, Johansson C, Elfstrand P O, Viander M, Lanner A. Prevalence of coeliac disease in diabetic children and adolescents in Sweden. Acta Paediatr. (1993);82:748-751. [pmid: 8241671].
Sjoberg K, Alm R, Ivarsson S A, Lindstrom C, Eriksson S. Prevalence and clinical significance of gliadin antibodies in healthy children and adults. Scand J Gastroenterol. (1994);29:248-254. [pmid: 8209185].
Sjoberg K, Eriksson K F, Bredberg A, Wassmuth R, Eriksson S. Screening for coeliac disease in adult insulin-dependent diabetes mellitus. J Intern Med. (1998);243:133-140. [pmid: 9566642].
Sjoberg K, Eriksson S. Regional differences in coeliac disease prevalence in Scandinavia?. Scand J Gastroenterol. (1999);34:41-45. [pmid: 10048731].
Smecuol E, Gonzalez D, Mautalen C, Siccardi A, Cataldi M, Niveloni S, Mazure R, Vazquez H, Pedreira S, Soifer G, Boerr L A, Maurino E, Bai J C. Longitudinal study on the effect of treatment on body composition and anthropometry of celiac disease patients. Am J Gastroenterol. (1997);92:639-643. [pmid: 9128314].
Spiekerkoetter U, Seissler J, Wendel U. General screening for celiac disease is advisable in children with type 1 diabetes. Horm Metab Res. (2002);34:192-195. [pmid: 11987028].
Stokes P L, Ferguson R, Holmes G K, Cooke W T. Familial aspects of coeliac disease. Quarterly Journal of Medicine. (1976);45:567-582. [pmid: 1005655].
Sulkanen S, Collin P, Laurila K, Maki M. IgA- and IgG-class antihuman umbilical cord antibody tests in adult coeliac disease. Scandinavian Journal of Gastroenterology. (1998);33:251-254. [pmid: 9548617].
Sulkanen S, Halttunen T, Laurila K, Kolho K L, Korponay-Szabo I R, Sarnesto A, Savilahti E, Collin P, Maki M. Tissue transglutaminase autoantibody enzyme-linked immunosorbent assay in detecting celiac disease. Gastroenterology. (1998);115:1322-1328. [pmid: 9834257].
Talal A H, Murray J A, Goeken J A, Sivitz W I. Celiac disease in an adult population with insulin-dependent diabetes mellitus: use of endomysial antibody testing. Am J Gastroenterol. (1997);92:1280-1284. [pmid: 9260789].
Talley N J, Valdovinos M, Petterson T M, Carpenter H A, Melton L J. Epidemiology of celiac sprue: a community-based study. Am J Gastroenterol. (1994);89:843-846. [pmid: 7864924].
Tesei N, Sugai E, Vazquez H, Smecuol E, Niveloni S, Mazure R, Moreno M L, Gomez J C, Maurino E, Bai J C. Antibodies to human recombinant tissue transglutaminase may detect coeliac disease patients undiagnosed by endomysial antibodies. Alimentary Pharmacology & Therapeutics. (2003);17:1415-1423. [pmid: 12786636].
Thomas A G, Phillips A D, Walker-Smith J A. The value of proximal small intestinal biopsy in the differential diagnosis of chronic diarrhoea. Arch Dis Child. (1992);67:741-743. [pmid: 1626996].
Thomason K, West J, Logan R F A, Coupland C, Holmes G K T. Fracture experience of patients with coeliac disease: a population based survey. Gut. (2003);52:518-522. [pmid: 12631662]. [pmcid: 1773600].
Trevisiol C, Not T, Berti I, Buratti E, Citta A, Neri E, Torre G, Martelossi S, Tommasini A, Alu A, Barillari G, Facchini S, Ventura A. Screening for coeliac disease in healthy blood donors at two immuno-transfusion centres in north-east Italy. Ital J Gastroenterol Hepatol. (1999);31:584-586. [pmid: 10604097].
Troncone R, Maurano F, Rossi M, Micillo M, Greco L, Auricchio R, Salerno G, Salvatore F, Sacchetti L. IgA antibodies to tissue transglutaminase: An effective diagnostic test for celiac disease. Journal of Pediatrics. (1999);134:166-171. [pmid: 9931524].
Troncone R, Mayer M, Spagnuolo F, Maiuri L, Greco L. Endomysial antibodies as unreliable markers for slight dietary transgressions in adolescents with celiac disease. J Pediatr Gastroenterol Nutr. (1995);21:69-72. [pmid: 8576818].
Tursi A, Brandimarte G, Giorgetti G M, Inchingolo C D. Effectiveness of the sorbitol HSUB2 breath test in detecting histological damage among relatives of coeliacs. Scand J Gastroenterol. (2003);38:727-731. [pmid: 12889558].
Unsworth D J, Lock R J, Harvey R F. Improving the diagnosis of coeliac disease in anaemic women. Br J Haematol. (2000);111:898-901. [pmid: 11122153].
Vahedi K, Mascart-Lemone F, Mary JY, Laberenne JE, Bouhnik Y, Morin MC, Velly C, Colombel JF, Matuchansky C (2000) Are Anti-Endomysial (AEM) and Anti-Transglutaminase (TTG) Antibodies Reliable Markers of Strict Diet Compliance in Adult Celiacs on a Gluten Free Diet (GFD)? Gastroenterology 118: AGA
Valdimarsson T, Franzen L, Grodzinsky E, Skogh T, Strom M. Is small bowel biopsy necessary in adults with suspected celiac disease and IgA anti-endomysium antibodies? 100% positive predictive value for celiac disease in adults. Digestive Diseases and Sciences. (1996);41:83-87. [pmid: 8565771].
Valentini R A, Andreani M L, Corazza G R, Gasbarrini G. IgA endomysium antibody: a valuable tool in the screening of coeliac disease but not its follow-up. Ital J Gastroenterol. (1994);26:279-282. [pmid: 7949263].
Valerio G, Maiuri L, Troncone R, Buono P, Lombardi F, Palmieri R, Franzese A. Severe clinical onset of diabetes and increased prevalence of other autoimmune diseases in children with coeliac disease diagnosed before diabetes mellitus. Diabetologia. (2002);45:1719-1722. [pmid: 12488963].
Valletta E A, Trevisiol D, Mastella G. IgA anti-gliadin antibodies in the monitoring of gluten challenge in celiac disease. J Pediatr Gastroenterol Nutr. (1990);10:169-173. [pmid: 2303968].
Van Mook W N K A, Bourass-Bremer I H D N, Bos L P, Verhoeven H M J M, Engels L G J B. The outcome of esophagogastroduodenoscopy (EGD) in asymptomatic outpatients with iron deficiency anemia after a negative colonoscopy. Eur J Intern Med. (2001);12:122-126. [pmid: 11297915].
Vasquez H, Mazure R, Gonzalez D, Flores D, Pedreira S, Niveloni S, Smecuol E, Maurino E, Bai J C. Risk of fractures in celiac disease patients: a cross-sectional, case-control study. Am J Gastroenterol. (2000);95:183-189. [pmid: 10638580].
Ventura A, Facchini S, Amantidu C, Andreotti M F, Andrighetto A, Baggiani A, Benedetti F, Bonati S, Buonaterra I, Capozzo M, Ciscato E, Cracco F, Ferrari G, Fornale M, Fusco F, Laverda E, Mardiciaro M, Nicolussi E, Pasinato L, Pittarello D, Pizio E, Salvadori R, Sambugaro D, Sassolino S, Spavanello V, Visan C T, Ziglio G, Zuffellato V. Searching for celiac disease in pediatric general practice. Clin Pediatr. (2001);40:575-577.
Vestergaard P, Mosekilde L. Fracture risk in patients with celiac Disease, Crohn's disease, and ulcerative colitis: a nationwide follow-up study of 16,416 patients in Denmark. Am J Epidemiol. (2002);156:1-10. [pmid: 12076883].
Vitoria J C, Arrieta A, Astigarraga I, Garcia-Masdevall D, Rodriguez-Soriano J. Use of serological markers as a screening test in family members of patients with celiac disease. J Pediatr Gastroenterol Nutr. (1994);19:304-309. [pmid: 7815262].
Vitoria J C, Arrieta A, Ortiz L, Ayesta A. Antibodies to human tissue transglutaminase for the diagnosis of celiac disease. Journal of Pediatric Gastroenterology and Nutrition. (2001);33:349-350. [pmid: 11593137].
Vitoria J C, Castano L, Rica I, Bilbao J R, Arrieta A, Garcia-Masdevall M D. Association of insulin-dependent diabetes mellitus and celiac disease: a study based on serologic markers. J Pediatr Gastroenterol Nutr. (1998);27:47-52. [pmid: 9669725].
Vogelsang H, Genser D, Wyatt J, Lochs H, Ferenci P, Granditsch G, Penner E. Screening for celiac disease: a prospective study on the value of noninvasive tests. American Journal of Gastroenterology. (1995);90:394-398. [pmid: 7872276].
Volta U, Bellentani S, Bianchi F B, Brandi G, De Franceschi L, Miglioli L, Granito A, Balli F, Tiribelli C. High prevalence of celiac disease in Italian general population. Dig Dis Sci. (2001);46:1500-1505. [pmid: 11478502].
Volta U, Molinaro N, De Franceschi L, Fratangelo D, Bianchi F B. IgA anti-endomysial antibodies on human umbilical cord tissue for celiac disease screening. Save both money and monkeys. Digestive Diseases and Sciences. (1995);40:1902-1905. [pmid: 7555440].
Wahab P J, Meijer Jos W R, Mulder Chris J J. Histologic follow-up of people with celiac disease on a gluten-free diet: slow and incomplete recovery. American Journal of Clinical Pathology. (2002);118:459-463. [pmid: 12219789].
Weile B, Krasilnikoff P A. Extremely low incidence rates of celiac disease in the Danish population of children. J Clin Epidemiol. (1993);46:661-664. [pmid: 8326351].
Weile I, Grodzinsky E, Skogh T, Jordal R, Cavell B, Krasilnikoff P A. High prevalence rates of adult silent coeliac disease, as seen in Sweden, must be expected in Denmark. APMIS. (2001);109:745-750. [pmid: 11900053].
West J, Logan R F A, Hill P G, Lloyd A, Lewis S, Hubbard R, Reader R, Holmes G K T, Khaw K-T. Seroprevalence, correlates, and characteristics of undetected coeliac disease in England. Gut. (2003);52:960-965. [pmid: 12801951]. [pmcid: 1773707].
West J, Logan Richard F A, Card T R, Smith C, Hubbard R. Fracture risk in people with celiac disease: a population-based cohort study. Gastroenterology. (2003);125:429-436. [pmid: 12891545].
Westman E, Ambler G R, Royle M, Peat J, Chan A. Children with coeliac disease and insulin dependent diabetes mellitus--growth, diabetes control and dietary intake. J Pediatr Endocrinol Metab. (1999);12:433-442. [pmid: 10821223].
Whelan A, Willoughby R, Weir D. Human umbilical vein endothelial cells: a new easily available source of endomysial antigens. European Journal of Gastroenterology & Hepatology. (1996);8:961-966. [pmid: 8930559].
Wolters V, Vooijs-Moulaert A, Burger H, Brooimans R, De Schryver J, Rijkers G, Houwen R. Human tissue transglutaminase enzyme linked immunosorbent assay outperforms both the guinea pig based tissue transglutaminase assay and anti-endomysium antibodies when screening for coeliac disease. European Journal of Pediatrics. (2002);161:284-287. [pmid: 12012226].