# Appendix G. Raw Pooled Data

All raw pooled data by antibody test and study types showing number of studies and total patient numbers.

AGA - ELISA
Population | Pooled Number | | IgA | | | | | Pooled Number | | IgG
| Studies | Patients | Sens | Spec | PPV | NPV | Prev | Studies | Patients | Sens | Spec | PPV | NPV | Prev
Case Control
Adults | 2 | 336 | 57.9 | 92.6 | 93.2 | 55.7 | 0.40 | 1 | 157 | 78.0 | 80.7 | 87.6 | 67.6 | 56.7
Children | 5 | 412 | 76.6 | 79.9 | 81.1 | 75.2 | 0.5 | 5 | 412 | 84.4 | 60.3 | 70.5 | 77.5 | 0.5
Both | 1 | 343 | 84.6 | 81.6 | 75.2 | 88.9 | 0.4 | 1 | 343 | 69.1 | 73.4 | 63.1 | 78.4 | 0.4
Relevant CP
Adults | 8 | 946 | 71.0 | 81.1 | 61.7 | 86.8 | 0.35 | 6 | 652 | 65.6 | 85.7 | 70.7 | 82.7 | 31.9
Children | 14 | 1382 | 80.1 | 89.9 | 78.7 | 90.7 | 0.3 | 12 | 1189 | 89.3 | 83.6 | 68.1 | 95.2 | 0.3
Both | 3 | 737 | 68.2 | 92.7 | 91.5 | 71.5 | 0.5 | 3 | 737 | 83.8 | 79.5 | 82.6 | 80.9 | 0.5

EMA - Monkey Esophagus IF
Study Population | Pooled Number | | IgA | | | | | Pooled Number | | IgG
| Studies | Patients | Sens | Spec | PPV | NPV | Prev | Studies | Patients | Sens | Spec | PPV | NPV | Prev
Case Control
Adults | 6 | 706 | 97.3 | 100.0 | 100.0 | 97.1 | 50.7 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Children | 12 | 1038 | 96.5 | 98.7 | 98.6 | 96.6 | 0.5 | 1* | 153 | 100 | 100 | 100 | 100 | 0.1
Both | 1 | 131 | 75.3 | 98.3 | 98.2 | 76.0 | 0.6 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Relevant CP
Adults | 5 | 692 | 95.0 | 99.4 | 98.1 | 98.5 | 22.4 | 1 | 89 | 39.3 | 98.4 | 91.7 | 77.9 | 0.14
Children | 6 | 868 | 93.2 | 95.4 | 88.3 | 97.4 | 0.3 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Both | 3 | 737 | 87.9 | 99.7 | 99.7 | 87.6 | 0.5 | n/a | n/a | n/a | n/a | n/a | n/a | n/a

* this study was conducted in CD patients known to be IgA-EMA negative, and 50% had IgA deficiency

EMA - Human Umbilical Cord - IF
Population | Pooled Number | | IgA | | | | | Pooled Number | | IgG
| Studies | Patients | Sens | Spec | PPV | NPV | Prev | Studies | Patients | Sens | Spec | PPV | NPV | Prev
Case Control
Adults | 5 | 578 | 90.3 | 100.0 | 100.0 | 93.7 | 37.2 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Children | 4 | 375 | 96.6 | 100.0 | 100.0 | 97.1 | 0.5 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Both | 2 | 428 | 92.5 | 99.6 | 99.5 | 93.8 | 0.5 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Relevant CP
Adults | 1 | 92 | 87.5 | 100.0 | 100.0 | 98.8 | 7.6 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Children | 2 | 172 | 70.5 | 86.7 | 64.6 | 89.5 | 0.3 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Both | n/a | n/a | n/a | n/a | n/a | n/a | n/a | n/a | n/a | n/a | n/a | n/a | n/a | n/a

tTG - Guinea Pig Liver - ELISA
Population | Pooled Number | | IgA | | | | | Pooled Number | | IgG
| Studies | Patients | Sens | Spec | PPV | NPV | Prev | Studies | Patients | Sens | Spec | PPV | NPV | Prev
Case Control
Adults | 3 | 368 | 83.4 | 97.1 | 97.0 | 84.2 | 45.1 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Children | 3 | 270 | 92.3 | 99.2 | 99.2 | 92.0 | 0.5 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Both | 3 | 559 | 91.2 | 94.7 | 94.3 | 91.8 | 0.5 | 1 | 85 | 61.5 | 100.0 | 100.0 | 44.4 | 0.8
Relevant CP
Adults | 2 | 327 | 100.0 | 94.2 | 66.7 | 100.0 | 15.6 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Children | 2 | 176 | 95.1 | 93.0 | 87.9 | 97.3 | 0.3 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Both | 1 | 111 | 91.7 | 98.4 | 97.8 | 93.9 | 0.4 | 1 | 111 | 22.9 | 98.4 | 91.7 | 62.6 | 0.4

tTG - Human Recombinant - ELISA
Population | Pooled Number | | IgA | | | | | Pooled Number | | IgG
| Studies | Patients | Sens | Spec | PPV | NPV | Prev | Studies | Patients | Sens | Spec | PPV | NPV | Prev
Case Control
Adults | 1 | 63 | 95.2 | 100.0 | 100.0 | 97.7 | 31.7 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Children | 2 | 115 | 95.3 | 98.0 | 98.4 | 94.3 | 0.6 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Both | 1 | 85 | 90.8 | 100.0 | 100.0 | 76.9 | 0.8 | 1 | 85 | 67.7 | 100.0 | 100.0 | 48.8 | 0.8
Relevant CP
Adults | 2 | 299 | 100.0 | 97.8 | 84.2 | 100.0 | 12.7 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Children | 1 | 101 | 96.2 | 100.0 | 100.0 | 96.1 | 0.5 | n/a | n/a | n/a | n/a | n/a | n/a | n/a
Both | 1 | 426 | 90.0 | 94.9 | 96.2 | 87.0 | 0.6 | n/a | n/a | n/a | n/a | n/a | n/a | n/a