# Appendix F. Modified QUOROM Flow Chart

## Modified QUOROM Flow Charts

Objective 1 - Sensitivity and Specificity of Tests for CD

Objective 2 - Prevalence and Incidence of CD

Objective 3 - Celiac Associated Lymphoma

Objective 4 - Expected Consequences of Testing for CD

Objective 5 - Promoting or Monitoring Adherence to a GFD