# Appendix E. Summary ROC Curves

Summary ROC curves as calculated by the methods of Moses and Shapiro (meta-analysis text). For all figures below, the middle curve is the summary ROC, the other curves are upper and lower 96% CI, and the vertical line is the point were sensitivity = specificity; dots are individual studies

## Figure 1. Summary ROC HLA average-risk with 95% Cls

[image]

## Figure 2. Summary ROC IgA-AGA-adults

[image]

## Figure 3. Summary ROC IgG-AGA-adults

[image]

## Figure 4. Summary ROC IgA-EMA-EM-adults

[image]

## Figure 5. Summary ROC IgA-EMA-HU-adults

[image]

## Figure 6. Summary ROC IgA-tTG-GP-adults

[image]

## Figure 7. Summary ROC IgA-tTG-HR-adults

[image]

## Figure 8. Summary ROC IgA-AGA-child

[image]

## Figure 9. Summary ROC IgG-AGA-child

[image]

## Figure 10. Summary ROC IgA-EMA-ME-child

[image]

## Figure 11. Summary ROC IgA-EMA-HU-child

[image]

## Figure 12. Summary ROC IgA-tTG-GP-child

[image]

## Figure 13. Summary ROC IgA-tTG-HR-child

[image]

## Figure 14. Summary ROC IgA-AGA-mixed-age populations

[image]

## FIgure 15. Summary ROC IgG-AGA-mixed-age populations

[image]

## Figure 16. Summary ROC IgA-EMA--ME-mixed-age populations

[image]

## Figure 17. Summary ROC IgA-tTG-GP-mixed-age populations

[image]