# Appendix B. Search Strategies

## Search Strategy 1

### Celiac 1 - Diagnostic Tests

#### Test 1. EMA

MEDLINE on DIALOG

1. s anti(w)endomysial(w)antibod? OR antiendomysial(w)antibod?
2. s anti(w)endomysium(w)antibod? OR antiendomysium(w)antibod?
3. s endomysial(w)antibod? OR endomysium(w)antibod? OR endomysial(w)autoantibod? OR endomysium(w)autoantibod?
4. s endomysial(n3)iga OR antiendomysial(n3)iga OR iga(n)ema
5. s endomysium(n3)iga OR antiendomysium(n3)iga OR igg(n)ema
6. s immunoglobulin?(n3)endomysial OR immunoglobulin?(n3)antiendomysial
7. s immunoglobulin?(n3)endomysium OR immunoglobulin?(n3)antiendomysium
8. s ema(n3)antibod? OR ema(n3)autoantibod? OR anti(w)ema OR ema(n3)positiv?
9. s aea AND (endomysial OR endomysium OR antiendomys?) OR aea(n3)positiv? OR aea(n2)igg OR aea(n2)iga
10. c 1 OR 2 OR 3 OR 4 OR 5 OR 6 OR 7 OR 8 OR 9
11. s (celiac OR celiacs OR coeliac OR coeliacs OR gluten OR glutens OR glutenin OR glutenins OR gliadin OR gliadins OR celiac disease/de) AND (ema OR aea)
12. s (celiac OR celiacs OR coeliac OR coeliacs OR gluten OR glutens OR glutenin OR glutenins OR gliadin OR gliadins OR celiac disease/de) AND autoantibod?(n2) positiv?
13. c 10 OR 11 OR 12
14. s epithelial(w)membrane(w)antigen
15. c 13 NOT 14
16. s s15/human
17. s s16/eng

EMBASE on DIALOG

1. s anti(w)endomysial(w)antibod? OR antiendomysial(w)antibod?
2. s anti(w)endomysium(w)antibod? OR antiendomysium(w)antibod?
3. s endomysial(w)antibod? OR endomysium(w)antibod? OR endomysial(w)autoantibod? OR endomysium(w)autoantibod? OR endomysium antibody/de
4. s endomysial(n3)iga OR antiendomysial(n3)iga OR iga(n)ema
5. s endomysium(n3)iga OR antiendomysium(n3)iga OR igg(n)ema
6. s immunoglobulin?(n3)endomysial OR immunoglobulin?(n3)antiendomysial
7. s immunoglobulin?(n3)endomysium OR immunoglobulin?(n3)antiendomysium
8. s ema(n3)antibod? OR ema(n3)autoantibod? OR anti(w)ema OR ema(n3)positiv?
9. s aea AND (endomysial OR endomysium OR antiendomys?) OR aea(n3)positiv? OR aea(n2)igg OR aea(n2)iga
10. c 1 OR 2 OR 3 OR 4 OR 5 OR 6 OR 7 OR 8 OR 9
11. s (celiac OR celiacs OR coeliac OR coeliacs OR gluten OR glutens OR glutenin OR glutenins OR gliadin OR gliadins OR celiac disease/de) AND (ema OR aea)
12. s (celiac OR celiacs OR coeliac OR coeliacs OR gluten OR glutens OR glutenin OR glutenins OR gliadin OR gliadins OR celiac disease/de) AND autoantibod?(n2)positiv?
13. c 10 OR 11 OR 12
14. s epithelial(w)membrane(w)antigen
15. c 13 not 14
16. s s15/human
17. s s16/eng

#### Test 2. tTG

MEDLINE on DIALOG

1. s tissue(w)transglutaminase?? OR tissue(w)trans(w)glutaminase??
2. s antitissue(w)transglutaminase?? OR anti(w)transglutaminase??
3. s human(w)transglutaminase?? OR antitransglutaminase??(n3)antibod?
4. s (immunoglobulin? OR immunoglobulin a/de OR immunoglobulin g/de) AND (transglutaminase OR transglutaminases)
5. s ttg(n3)antibod? OR ttg(n3)autoantibod? OR ttg(w)(kit OR kits) OR ttga OR httg OR anti(w2)ttg OR human(w)ttg OR elisa(n)ttg OR attga
6. s (transglutaminase?? AND antibod?) OR (transglutaminase?? AND autoantibod?)
7. s transglutaminase??(n3)iga OR transglutaminase??(n3)igg OR tg2(n5)transglutaminase?? OR human(w) recombinant(w)tg2
8. s anti(w)gamma(w)glutamyltransferase AND (antibod? OR autoantibod?)
9. c 1 OR 2 OR 3 OR 4 OR 5 OR 6 OR 7 OR 8
10. s (celiac OR celiacs OR coeliac OR coeliacs OR gluten OR glutens OR glutenin OR glutenins OR gliadin OR gliadins OR celiac disease/de) AND (transglutaminase OR transglutaminases OR ttg OR tg2)
11. c 9 OR 10
12. s s11/human
13. s s12/eng

EMBASE on DIALOG

1. s tissue(w)transglutaminase?? OR tissue(w)trans(w)glutaminase??
2. s antitissue(w)transglutaminase?? OR anti(w)transglutaminase??
3. s human(w)transglutaminase?? OR antitransglutaminase??(n3)antibod?
4. s immunoglobulin OR immunoglobulin a/de OR immunoglobulin a1/de OR immunoglobulin a2/de
5. s immunoglobulin g/de OR immunoglobulin g1/de OR immunoglobulin g2/de OR immunoglobulin g2a/de OR immunoglobulin g2b/de OR immunoglobulin g3/de OR immunoglobulin g4/de
6. s transglutaminase OR transglutaminases
7. c 4 OR 5
8. c 7 AND 6
9. s ttg(n3)antibod? OR ttg(n3)autoantibod? OR ttg(w)(kit OR kits OR assay) OR ttga OR httg OR anti(w2)ttg OR human(w)ttg OR elisa(n)ttg OR attga
10. s (transglutaminase?? AND antibod?) OR (transglutaminase?? AND autoantibod?)
11. s transglutaminase??(n3)iga OR transglutaminase??(n3)igg OR tg2(n5)transglutaminase?? OR human(w) recombinant(w)tg2
12. s anti(w)gamma(w)glutamyltransferase AND (antibod? OR autoantibod?)
13. c 1 OR 2 OR 3 OR 8 OR 9 OR 10 OR 11 OR 12
14. s (celiac OR celiacs OR coeliac OR coeliacs OR gluten OR glutens OR glutenin OR glutenins OR gliadin OR gliadins OR celiac disease/de) AND (transglutaminase OR transglutaminases OR ttg OR tg2)
15. c 13 OR 14
16. s s15/human
17. s s16/eng

#### Test 3. AGA

MEDLINE on DIALOG

1. s gliadin(w)antibod? OR antigliadin(w)antibod? OR iga(n3)antigliadin OR igg(n3)antigliadin
2. s antigliadin AND (serology OR serological)
3. s iga(n2)aga OR igg(n2)aga OR aga(n3)positive? OR anti(w)aga
4. s (celiac OR celiacs OR coeliac OR coeliacs OR gluten OR glutens OR glutenin OR glutenins OR gliadin OR gliadins OR celiac disease/de) AND (aga OR antigliadin?)
5. c 1 OR 2 OR 3
6. c 5 OR 4
7. s s6/human
8. s s7/eng

EMBASE on DIALOG

1. s gliadin(w)antibod? OR antigliadin(w)antibod? OR iga(n3)antigliadin OR igg(n3)antigliadin
2. s antigliadin AND (serology OR serological)
3. s iga(n2)aga OR igg(n2)aga OR aga(n3)positive? OR anti(w)aga
4. s (celiac OR celiacs OR coeliac OR coeliacs OR gluten OR glutens OR glutenin OR glutenins OR gliadin OR gliadins OR celiac disease/de) AND (aga OR antigliadin? OR anti(w)gliadin?)
5. c 1 OR 2 OR 3
6. c 5 OR 4
7. s s6/human
8. s s7/eng

#### Test 4. HLA DQ2/DQ8

MEDLINE on DIALOG

1. s (leukocyte OR leukocytes OR leucocyte OR leucocytes) AND (antigen OR antigens)
2. s hla OR hla-dq antigens/de OR hla antigens/de OR hladq OR histocompatibility antigens/de OR histocompatibility testing/de OR histocompatibility
3. c 1 OR 2
4. s dq2? OR dq8? OR hladq2? OR hladq8? OR d2? OR d8?
5. c 3 AND 4
6. s celiac OR celiacs OR coeliac OR coeliacs OR gluten OR glutens OR glutenin OR glutenins OR gliadin OR gliadins OR celiac disease/de
7. s hla(w)antigen?? OR hla antigens/de OR hla-dq antigens/de
8. c 6 AND 7
9. c 5 OR 8
10. s s8/human
11. s s9/eng

EMBASE on DIALOG

1. s (leukocyte OR leukocytes OR leucocyte OR leucocytes) AND antigen
2. s (leukocyte OR leukocytes OR leucocyte OR leucocytes) AND antigens
3. s hla OR hla dq antigen/de OR hla antigen/de OR hladq OR histocompatibility antigen/de OR histocompatibility test/de OR histocompatibility/ti,ab,de
4. c 1 OR 2 OR 3
5. s dq2? OR dq8? OR hladq2? OR hladq8? OR d2? OR d8?
6. c 4 AND 5
7. s celiac OR celiacs OR coeliac OR coeliacs OR gluten OR glutens OR glutenin OR glutenins OR gliadin OR gliadins
8. s hla(w)antigens?? OR hla antigen/de OR hla dq antigen/de
9. c 7 AND 8
10. c 6 OR 9
11. s s10/human
12. s s11/eng

#### Test 5. Small bowel biopsy

MEDLINE on DIALOG

1. s celiac???(w)disease OR coeliac???(w)disease OR celiac(w)sprue OR coeliac(w)sprue OR celiac(w)syndrome OR coeliac(w)syndrome
2. s celiacs OR coeliacs OR celiac disease/de
3. s silent(w)celiac OR silent(w)coeliac OR asymptomatic(w)celiac OR asymptomatic(w)coeliac OR undetected(n3)(celiac OR coeliac)
4. s subclinical(w)celiac OR subclinical(w)coeliac OR sub(w)clinical(w)celiac OR sub(w)clinical(w)coeliac OR undiagnosed(n3)celiac OR undiagnosed(n3)coeliac
5. s nontropical(w)sprue OR non(w)tropical(w)sprue OR endemic(w)sprue
6. s gluten(n3)enteropath? OR gluten(n3)sensitiv? OR gluten(n3)hypersensitive? OR gluten(n3)intoleran? OR glutenin??(n3)hypersensitiv? OR glutenin??(n3) sensitiv? OR glutenin??(n3)intoleran?
7. s gliadin(n3)hypersentitiv? OR gliadin(n3)intoleran?
8. s wheat(n3)hypersensitiv? OR wheat(n3)intoleran? OR wheat hypersensitivity/de
9. s (wheat OR triticum OR gluten) AND food hypersensitivity/de
10. c 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11. s celiac disease(l)pathology OR celiac disease(l)diagnosis OR wheat hypersensivitity(l)diagnosis OR wheat hypersensitivity(l)pathology
12. s (wheat OR triticum OR gluten) AND food hypersensitivity(l)diagnosis
13. s (wheat OR triticum OR gluten) AND food hypersensitivity(l)pathology
14. c 11 or 12 or 13
15. s intestine, small(l)pathology OR duodenum(l)pathology OR jejunum(l)pathology OR ileum(l)pathology OR small(n2)bowel/ti,ab OR small(n2)intestine?/ti,ab
16. s biopsy! OR biopsy/ti,ab OR biopsies/ti,ab
17. c 14 AND 15 AND 16
18. s small(w)(bowel OR intestine OR intestines) OR intestinal(w)mucosa
19. c 10 AND 16 AND 18
20. s (villi OR villus OR villous OR microvilli)(n3)atroph?
21. c (10 AND 20) OR (14 AND 20)
22. c 17 OR 19 OR 21
23. s s22/human
24. s s23/eng

EMBASE on DIALOG

1. s celiac???(w)disease OR coeliac???(w)disease OR celiac(w)sprue OR coeliac(w)sprue OR celiac(w)syndrome OR coeliac(w)syndrome
2. s celiacs OR coeliacs OR celiac disease/de
3. s silent(w)celiac OR silent(w)coeliac OR asymptomatic(w)celiac OR asymptomatic(w)coeliac OR undetected(n3)(celiac OR coeliac)
4. s subclinical(w)celiac OR subclinical(w)coeliac OR sub(w)clinical(w)celiac OR sub(w)clinical(w)coeliac OR undiagnosed(n3)celiac OR undiagnosed(n3)coeliac
5. s nontropical(w)sprue OR non(w)tropical(w)sprue OR endemic(w)sprue
6. s gluten(n3)enteropath? OR gluten(n3)sensitiv? OR gluten(n3)hypersensitive? OR gluten(n3)intoleran? OR glutenin??(n3)hypersensitiv? OR glutenin??(n3) sensitiv? OR glutenin??(n3)intoleran?
7. s gliadin(n3)hypersentitiv? OR gliadin(n3)intoleran?
8. s wheat(n3)hypersensitiv? OR wheat(n3)intoleran? OR wheat allergy/de
9. s (wheat OR triticum OR gluten OR glutens) AND food allergy/de
10. c 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11. s small intestine/de OR duodenum/ti,ab,de OR jejunum/ti,ab,de OR ileum/ti,ab,de OR small(n2)bowel/ti,ab OR small(n2)intestine?/ti,ab OR duodenal/ti,ab OR jejunal/ti,ab OR ileal/ti,ab
12. s dc=a3.60.70? [small intestine]
13. s small(w)(bowel OR intestine OR intestines) OR intestinal(w)mucosa
14. s intestine mucosa/de or duodenum mucosa/de OR jejunum mucosa/de OR ileum mucosa/de
15. c 11 OR 12 OR 13 OR 14
16. s biopsy/ti,ab,de OR biopsies/ti,ab
17. c 15 AND 16
18. s intestine biopsy/de OR duodenum biopsy/de OR jejunum biopsy/de OR ileum biopsy/de
19. c 17 OR 18
20. c 10 AND 19
21. s (villi OR villus OR villous OR microvilli)(n3)atroph?
22. c 10 AND 21
23. c 20 OR 22
24. s s23/human
25. s s24/eng

### Celiac 2 - Epidemiology

MEDLINE on DIALOG

1. s celiac???(w)disease OR coeliac???(w)disease OR celiac(w)sprue OR coeliac(w)sprue OR celiac(w)syndrome OR coeliac(w)syndrome
2. s celiacs OR coeliacs OR celiac disease/de
3. s silent(w)celiac OR silent(w)coeliac OR asymptomatic(w)celiac OR asymptomatic(w)coeliac OR undetected(n3)(celiac OR coeliac)
4. s subclinical(w)celiac OR subclinical(w)coeliac OR sub(w)clinical(w)celiac OR sub(w)clinical(w)coeliac OR undiagnosed(n3)celiac OR undiagnosed(n3)coeliac
5. s nontropical(w)sprue OR non(w)tropical(w)sprue OR endemic(w)sprue
6. s gluten(n3)enteropath? OR gluten(n3)sensitiv? OR gluten(n3)hypersensitive? OR gluten(n3)intoleran? OR glutenin??(n3)hypersensitiv? OR glutenin??(n3) sensitiv? OR glutenin??(n3)intoleran?
7. s gliadin(n3)hypersentitiv? OR gliadin(n3)intoleran?
8. s wheat(n3)hypersensitive? OR wheat(n3)intoleran? OR wheat hypersensitivity/de
9. s (wheat OR triticum OR gluten) AND food hypersensitivity/de
10. c 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11. s celiac disease(l)epidemiology OR celiac disease(l)ethnology OR wheat hypersensitivity(l)epidemiology OR wheat hypersensitivity(l)ethnology
12. s (wheat OR triticum OR gluten) AND food hypersensitivity(l)epidemiology
13. s (wheat OR triticum OR gluten) AND food hypersensitivity(l)ethnology
14. s epidemiolog?/ti,de OR occurrence/ti,de OR prevalence/ti,de OR incidence/ti,de OR pedigree/de OR seroprevalence OR seroepidemiol? OR epidemiologic studies! OR epidemiologic measurements/de [check!!]
15. s population characteristics! OR population! OR demography! OR demographic?/ti,ab OR population?/ti,de
16. s minority groups/de OR ethnic groups! OR racial stocks!
17. s anemia(w2)iron(w)deficiency/de OR anemia(w)hypochromic/de OR iron(w)deficiency(w)anemia OR osteoporosis/ti,ab,de OR diabetes mellitus, insulin-dependent! OR juvenile(w)diabetes
18. s diabetes AND type(w)(1 OR I OR one)
19. s celiac disease(l)genetics OR gluten(l)genetics OR wheat hypersensitivity(l)genetics
20. s (wheat OR triticum OR gluten) AND food hypersensitivity(l)genetics
21. s family! OR genetic predisposition to disease! OR genetic(w)predisposition OR family(n3)(member OR members) OR familial
22. s family/ti,ab OR families/ti,ab OR familial/ti,ab OR brother/ti,ab OR brothers/ti,ab OR sister/ti,ab OR sisters/ti,ab OR aunt/ti,ab OR aunts/ti,ab OR uncle/ti,ab OR uncles/ti,ab OR cousin/ti,ab OR cousins/ti,ab
23. s parent/ti,ab OR parents/ti,ab OR mother/ti,ab OR mothers/ti,ab OR father/ti,ab OR fathers/ti,ab OR wife/ti,ab OR wives/ti,ab OR husband/ti,ab OR husbands/ti,ab
24. s son/ti,ab OR sons/ti,ab OR daughter/ti,ab OR daughters/ti,ab OR children/ti,ab OR relatives/ti,ab OR sibling/ti,ab OR siblings/ti,ab OR offspring/ti,ab
25. c 21 OR 22 OR 23 OR 24
26. c 19 OR 20
27. c 25 AND 26
28. c 14 OR 15 OR 16 OR 17 OR 18
29. c 10 AND 28
30. c 27 OR 29 OR 11 OR 12 OR 13
31. s s30/human
32. s s31/eng
33. s animal/de
34. c 32 NOT 33

EMBASE on DIALOG

1. s celiac???(w)disease OR coeliac???(w)disease OR celiac(w)sprue OR coeliac(w)sprue OR celiac(w)syndrome OR coeliac(w)syndrome
2. s celiacs OR coeliacs OR celiac disease/de
3. s silent(w)celiac OR silent(w)coeliac OR asymptomatic(w)celiac OR asymptomatic(w)coeliac OR undetected(n3)(celiac OR coeliac)
4. s subclinical(w)celiac OR subclinical(w)coeliac OR sub(w)clinical(w)celiac OR sub(w)clinical(w)coeliac OR undiagnosed(n3)celiac OR undiagnosed(n3)coeliac
5. s nontropical(w)sprue OR non(w)tropical(w)sprue OR endemic(w)sprue OR refractory(w)sprue
6. s gluten(n3)enteropath? OR gluten(n3)sensitiv? OR gluten(n3)hypersensitive? OR gluten(n3)intoleran? OR glutenin??(n3)hypersensitiv? OR glutenin??(n3) sensitiv? OR glutenin??(n3)intoleran?
7. s gliadin(n3)hypersentitiv? OR gliadin(n3)intoleran?
8. s wheat(n3)hypersensitive? OR wheat(n3)intoleran? OR wheat allergy/de OR cereal(w)allergy
9. s (wheat OR triticum OR gluten?? OR glutinin??) AND (food allergy/de OR allergy/de OR hypersensitivity/de OR food allergen/de)
10. c 1 OR 2 OR 3 OR 4 OR 5 OR 6 OR 7 OR 8 OR 9
11. s epidemiology/de,id OR dc=c1.270? OR epidemiolog?/ti,ab OR seroepidemiol? OR epidemiological data/de
12. s occurrence/ti,de OR prevalence/ti,de OR incidence/ti,de OR pedigree/ti,de OR pedigree analysis/de OR dc=g1.385.170? OR seroprevalence
13. s dc= g1.250.710.715? OR dc= i1.700? OR demography/ti,ab,de OR demographic?/ti,ab OR population?/ti,de OR population research/de OR population risk/de
14. s minority(w)group?? OR ethnic(w)group?? OR minorities/ti,ab OR dc=g1.750? OR dc=i1.275? OR dc=m2? OR ethnology/ti,ab,de OR ethnic difference/de OR ethnicity/ti,ab
15. s iron(w)deficiency(w)anemia OR iron deficiency anemia/de OR anemia(n3)hypochromic/ti,ab
16. s osteoporosis/ti,ab,de OR dc= c2.275.540.110.650?
17. s insulin dependent diabetes mellitus/de OR juvenile(w)diabetes OR insulin(w)dependent(w)diabetes
18. s diabetes AND type(w)(1 OR i OR one)
19. s familial disease/de OR family study/de OR familial incidence/de
20. c 11 OR 12 OR 13 OR 14 OR 15 OR 16 OR 17 OR 18 OR 19
21. s celiac disease/de OR gluten??/ti,ab OR wheat allergy/de OR cereal(w)allergy
22. s (wheat OR triticum OR gluten?? OR glutinin??) AND (food allergy/de OR allergy/de OR hypersensitivity/de OR food allergen/de)
23. c 21 OR 22
24. s genetics/de OR q1.340?
25. c 23 AND 24
26. s genetic(w)predisposition OR family(n3)(member OR members)
27. s family/ti,ab OR families/ti,ab OR familial/ti,ab OR brother/ti,ab OR brothers/ti,ab OR sister/ti,ab OR sisters/ti,ab OR aunt/ti,ab OR aunts/ti,ab OR uncle/ti,ab OR uncles/ti,ab OR cousin/ti,ab OR cousins/ti,ab
28. s parent/ti,ab OR parents/ti,ab OR mother/ti,ab OR mothers/ti,ab OR father/ti,ab OR fathers/ti,ab OR wife/ti,ab OR wives/ti,ab OR husband/ti,ab OR husbands/ti,ab
29. s son/ti,ab OR sons/ti,ab OR daughter/ti,ab OR daughters/ti,ab OR children/ti,ab OR relatives/ti,ab OR sibling/ti,ab OR siblings/ti,ab OR offspring/ti,ab
30. c 26 OR 27 OR 28 OR 29
31. c 25 AND 30
32. c 10 AND 20
33. c 31 OR 32
34. s celiac disease(l)epidemiology
35. s (celiac disease/de OR wheat allergy/de OR cereal(w)allergy) AND epidemiology/de
36. s (wheat OR triticum OR gluten?? OR glutinin??) AND (food allergy/de OR allergy/de OR hypersensitivity/de OR food allergen/de) AND epidemiology/de
37. c 34 OR 35 OR 36
38. c 33 OR 37
39. s s38/human
40. s s39/eng

### Celiac 3 - Lymphomas

MEDLINE on DIALOG

1. s celiac???(w)disease OR coeliac???(w)disease OR celiac(w)sprue OR coeliac(w)sprue OR celiac(w)syndrome OR coeliac(w)syndrome
2. s celiacs OR coeliacs OR celiac disease/de
3. s silent(w)celiac OR silent(w)coeliac OR asymptomatic(w)celiac OR asymptomatic(w)coeliac OR undetected(n3)(celiac OR coeliac)
4. s subclinical(w)celiac OR subclinical(w)coeliac OR sub(w)clinical(w)celiac OR sub(w)clinical(w)coeliac OR undiagnosed(n3)celiac OR undiagnosed(n3)coeliac
5. s nontropical(w)sprue OR non(w)tropical(w)sprue OR endemic(w)sprue
6. s gluten(n3)enteropath? OR gluten(n3)sensitiv? OR gluten(n3)hypersensitive? OR gluten(n3)intoleran? OR glutenin??(n3)hypersensitiv? OR glutenin??(n3) sensitiv? OR glutenin??(n3)intoleran?
7. s gliadin(n3)hypersentitiv? OR gliadin(n3)intoleran?
8. s wheat(n3)hypersensitive? OR wheat(n3)intoleran? OR wheat hypersensitivity/de
9. s (wheat OR triticum OR gluten) AND food hypersensitivity/de
10. c 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11. s (villi OR villus OR villous OR microvilli)(n3)atroph?
12. c 10 OR 11
13. s lymphoma/ti,ab,de OR lymphomas/ti,ab,de OR lymphoma! OR hodgkin?/ti,ab,de
14. s intestine/ti,ab,de OR intestinal/ti,ab,de OR duodenum/ti,ab,de OR duodenal/ti,ab.de OR jejunum/ti,ab,de OR jejunal/ti,ab,de OR ileum/ti,ab,de OR ileal/ti,ab,de
15. s small(n2)bowel/ti,ab OR small(n2)intestine?/ti,ab OR large(n2)intestine?/ti,ab OR large(n2)bowel/ti,ab OR intestines!
16. s gastric/ti,ab,de OR gastro?/ti,ab,de OR gi/ti,ab OR stomach/ti,ab,de OR pylorus/ti,ab,de OR pyloric/ti,ab,de OR esophagogastr?
17. c 14 or 15 or 16
18. c 12 AND 13 AND 17
19. s s18/human
20. s s19/eng

EMBASE on DIALOG

1. s celiac???(w)disease OR coeliac???(w)disease OR celiac(w)sprue OR coeliac(w)sprue OR celiac(w)syndrome OR coeliac(w)syndrome
2. s celiacs OR coeliacs OR celiac disease/de
3. s silent(w)celiac OR silent(w)coeliac OR asymptomatic(w)celiac OR asymptomatic(w)coeliac OR undetected(n3)(celiac OR coeliac)
4. s subclinical(w)celiac OR subclinical(w)coeliac OR sub(w)clinical(w)celiac OR sub(w)clinical(w)coeliac OR undiagnosed(n3)celiac OR undiagnosed(n3)celiac
5. s nontropical(w)sprue OR non(w)tropical(w)sprue OR endemic(w)sprue
6. s gluten(n3)enteropath? OR gluten(n3)sensitiv? OR gluten(n3)hypersensitive? OR gluten(n3)intoleran? OR glutenin??(n3)hypersensitiv? OR glutenin??(n3) sensitiv? OR glutenin??(n3)intoleran?
7. s gliadin(n3)hypersentitiv? OR gliadin(n3)intoleran? Or gluten free diet/de OR gluten(w)free
8. s wheat(n3)hypersensitive? OR wheat(n3)intoleran? OR wheat allergy/de OR cereal(w)allergy
9. s (wheat OR triticum OR gluten?? OR glutinin??) AND (food allergy/de OR allergy/de OR hypersensitivity/de)
10. c 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11. s (villi OR villus OR villous OR microvilli)(n3)atroph?
12. s refractory/ti,ab OR non(w)respond?/ti,ab OR nonrespond?/ti,ab OR non(w)responsiv?/ti,ab OR nonresponsiv?/ti,ab
13. s sprue OR celiac OR coeliac OR celiac disease/de
14. c 12 AND 13
15. c 10 OR 11 OR 14
16. s lymphoma/ti,ab,de OR lymphomas/ti,ab,de OR hodgkin?/ti,ab,de
17. s dc = c2.385.520.500.510? OR dc = c2.385.520.510.500? OR dc = c6.610.50.50? OR dc = c6.610.75.520.510? [var. lymphoma]
18. c 16 OR 17
19. s small intestine/de OR small(n2)bowel/ti,ab OR small(n2)intestine?/ti,ab OR duodenum/ti,ab,de OR duodenal/ti,ab OR jejunum/ti,ab,de OR jejunal/ti,ab OR ileum/ti,ab,de OR ileal/ti,ab
20. s large(n2)intestine?/ti,ab OR large(n2)bowel/ti,ab OR cecum/ti,ab,de OR colon/ti,ab,de OR colonic/ti,ab,de OR rectum/ti,ab,de OR rectal/ti,ab,de OR anus/ti,ab,de
21. s intestine/ti,ab,de OR intestinal/ti,ab,de OR dc = a3? [digestive system]
22. s intestine mucosa/de OR duodenum mucosa/de OR jejunum mucosa/de OR ileum mucosa/de OR intestinal(w)mucosa OR colon mucosa/de OR rectum mucosa/de OR small intestine mucosa/de
23. s gastric/ti,ab,de OR gastro?/ti,ab,de OR gi/ti,ab OR stomach/ti,ab,de OR cardia/ti,ab,de OR pylorus/ti,ab,de OR pyloric/ti,ab,de OR esophagogastr?
24. s digestive system cancer/de OR dc = c2.220.230.210? OR dc = c2.220.230.210? [digestive system cancer]
25. c 19 OR 20 OR 21 OR 22 OR 23 OR 24
26. c 15 AND 18 AND 25
27. s stomach lymphoma/de OR intestine lymphoma/de
28. c 15 AND 27
29. c 26 OR 28
30. s s29/human
31. s s30/eng

### Celiac 4 - Screening

MEDLINE on DIALOG

1. s celiac???(w)disease OR coeliac???(w)disease OR celiac(w)sprue OR coeliac(w)sprue OR celiac(w)syndrome OR coeliac(w)syndrome
2. s celiacs OR coeliacs OR celiac disease/de
3. s silent(w)celiac OR silent(w)coeliac OR asymptomatic(w)celiac OR asymptomatic(w)coeliac OR undetected(n3)(celiac OR coeliac)
4. s subclinical(w)celiac OR subclinical(w)coeliac OR sub(w)clinical(w)celiac OR sub(w)clinical(w)coeliac OR undiagnosed(n3)celiac OR undiagnosed(n3)coeliac
5. s nontropical(w)sprue OR non(w)tropical(w)sprue OR endemic(w)sprue
6. s gluten(n3)enteropath? OR gluten(n3)sensitiv? OR gluten(n3)hypersensitive? OR gluten(n3)intoleran? OR glutenin??(n3)hypersensitiv? OR glutenin??(n3) sensitiv? OR glutenin??(n3)intoleran?
7. s gliadin(n3)hypersentitiv? OR gliadin(n3)intoleran?
8. s wheat(n3)hypersensitive? OR wheat(n3)intoleran? OR wheat hypersensitivity/de
9. s (wheat OR triticum OR gluten) AND food hypersensitivity/de
10. c 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11. s screen/ti,ab OR screens/ti,ab OR screening/ti,ab OR screened/ti,ab OR mass screening!
12. c 10 AND 11
13. s celiac disease(l)diagnosis OR celiac disease(l)pathology
14. s “sensitivity and specificity”/de
15. s physician's practice patterns/de
16. s reference standards/de OR quality control/de OR evaluation studies/de OR predictive value of tests/de OR incidental findings/de
17. s reproducibility of results/de OR physical examination(l)standards OR diagnosis, differential/de OR diagnostic errors! OR follow-up studies/de
18. s public health/de OR public health practice/de OR population surveillance/de OR clinical protocols/de OR critical pathways/de
19. s quality assurance, health care! OR guideline adherence/de OR social control, formal/de OR “outcome assessment (health care)”/de
20. c 14 or 15 or 16 or 17 or 18 or 19
21. c 13 AND 20
22. c 12 OR 21
23. s s22/human
24. s s23/eng

EMBASE on DIALOG

1. s celiac???(w)disease OR coeliac???(w)disease OR celiac(w)sprue OR coeliac(w)sprue OR celiac(w)syndrome OR coeliac(w)syndrome
2. s celiacs OR coeliacs OR celiac disease/de
3. s silent(w)celiac OR silent(w)coeliac OR asymptomatic(w)celiac OR asymptomatic(w)coeliac OR undetected(n3)(celiac OR coeliac)
4. s subclinical(w)celiac OR subclinical(w)coeliac OR sub(w)clinical(w)celiac OR sub(w)clinical(w)coeliac OR undiagnosed(n3)celiac OR undiagnosed(n3)coeliac
5. s nontropical(w)sprue OR non(w)tropical(w)sprue OR endemic(w)sprue
6. s gluten(n3)enteropath? OR gluten(n3)sensitiv? OR gluten(n3)hypersensitiv? OR gluten(n3)intoleran? OR glutenin??(n3)hypersensitiv? OR glutenin??(n3) sensitiv? OR glutenin??(n3)intoleran?
7. s gliadin(n3)hypersentitiv? OR gliadin(n3)intoleran?
8. s wheat(n3)hypersensitiv? OR wheat(n3)intoleran?
9. s (wheat OR triticum OR gluten) AND (food allergy/de OR hypersensitivity/de)
10. c 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11. s mass screening/de OR mass(w)screen? OR genetic screening/de OR genetic(w)screen? OR newborn screening/de OR newborn??(n3)screen?
12. 10 AND 11
13. s screen/ti,ab OR screens/ti,ab OR screening/ti,ab OR screened/ti,ab
14. s dc=J2.10? [controlled study]
15. s dc=J2.40.10? [clinical study]
16. s dc=J2.50? [methodology]
17. s evaluation(w)study OR evaluation(w)studies OR physical examination/de OR follow-up studies/de
18. s dc=E1.215? [diagnosis]
19. s dc=N7.700? [practice guideline]
20. s dc=Q1.550.75? [social medicine]
21. c 14 or 15 or 16 or 17 or 18 or 19 or 20
22. c 10 AND 13 AND 21
23. c 12 OR 22
24. s s23/human
25. s s24/eng

CAB and AGRICOLA on DIALOG

1. s celiac???(w)disease OR coeliac???(w)disease OR celiac(w)sprue OR coeliac(w)sprue OR celiac(w)syndrome OR coeliac(w)syndrome
2. s celiacs OR coeliacs OR celiac syndrome/de
3. s silent(w)celiac OR silent(w)coeliac OR asymptomatic(w)celiac OR asymptomatic(w)coeliac OR undetected(n3)(celiac OR coeliac)
4. s subclinical(w)celiac OR subclinical(w)coeliac OR sub(w)clinical(w)celiac OR sub(w)clinical(w)coeliac OR undiagnosed(n3)celiac OR undiagnosed(n3)coeliac
5. s nontropical(w)sprue OR non(w)tropical(w)sprue OR endemic(w)sprue
6. s gluten(n3)enteropath? OR gluten(n3)sensitiv? OR gluten(n3)hypersensitiv? OR gluten(n3)intoleran? OR glutenin??(n3)hypersensitiv? OR glutenin??(n3) sensitiv? OR glutenin??(n3)intoleran?
7. s gliadin(n3)hypersentitiv? OR gliadin(n3)intoleran?
8. s wheat(n3)hypersensitiv? OR wheat(n3)intoleran?
9. s (wheat OR triticum OR gluten) AND (food allergies/de OR hypersensitivity/de)
10. c 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11. s mass(w)screen? OR genetic(w)screen? OR newborn??(n3)screen?
12. c 10 AND 11
13. s screen/ti,ab OR screens/ti,ab OR screening/ti,ab OR screened/ti,ab
14. s evaluation(w)study OR evaluation(w)studies
15. c 10 AND 13 AND 14
16. c 12 OR 15
17. s s16/human
18. s s17/eng

PsycInfo on DIALOG

1. s celiac???(w)disease OR coeliac???(w)disease OR celiac(w)sprue OR coeliac(w)sprue OR celiac(w)syndrome OR coeliac(w)syndrome
2. s celiacs OR coeliacs
3. s silent(w)celiac OR silent(w)coeliac OR asymptomatic(w)celiac OR asymptomatic(w)coeliac OR undetected(n3)(celiac OR coeliac)
4. s subclinical(w)celiac OR subclinical(w)coeliac OR sub(w)clinical(w)celiac OR sub(w)clinical(w)coeliac OR undiagnosed(n3)celiac OR undiagnosed(n3)coeliac
5. s nontropical(w)sprue OR non(w)tropical(w)sprue OR endemic(w)sprue
6. s gluten(n3)enteropath? OR gluten(n3)sensitiv? OR gluten(n3)hypersensitiv? OR gluten(n3)intoleran? OR glutenin??(n3)hypersensitiv? OR glutenin??(n3) sensitiv? OR glutenin??(n3)intoleran?
7. s gliadin(n3)hypersentitiv? OR gliadin(n3)intoleran?
8. s wheat(n3)hypersensitiv? OR wheat(n3)intoleran?
9. s (wheat OR triticum OR gluten) AND food allergies/de
10. c 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11. s mass(w)screen? OR genetic(w)screen? OR newborn??(n3)screen? OR screening/de OR screening tests/de OR health screening/de
12. c 10 AND 11
13. s screen/ti,ab OR screens/ti,ab OR screening/ti,ab OR screened/ti,ab
14. s evaluation(w)study OR evaluation(w)studies OR physical examination/de OR followup studies/de OR evaluation/de
15. c 10 AND 13 AND 14
16. c 12 OR 15
17. s s16/human
18. s s17/eng

Sociological Abstracts at CAB

Limits set to English

1. celiac (KW) OR celiacs (KW) OR coeliac (KW) OR coeliacs (KW)
2. wheat (KW) OR gluten* (KW) OR gliadin* OR food (DE) OR foods (KW)
3. allergy (KW) OR allergies (KW) OR hypersensitivit* (KW) OR sensitive* (KW) OR intolerance* (KW)
4. mass public (DE) OR screen (KW OR screens (KW) OR screening (KW) OR screened (KW)
5. 1 AND 4
6. 2 and 3 AND 4
7. 5 OR 6

### Celiac 5 - Dietary Compliance

MEDLINE on DIALOG:

[underlined: Part 1]

1. s celiac disease(l)psychology OR diet therapy(l)education OR diet therapy(l)methods OR diet therapy(l)standards OR diet therapy(l)trends OR diet therapy(l)utilization OR diet therapy(l)psychology
2. s diet(l)methods OR diet(l)trends OR diet(l)psychology OR diet(l)standards OR diet(l)utilization
3. s psychological tests/de OR health behavior/de OR patient acceptance of health care! OR health education/de OR patient education/de OR nutrition(l)education OR teaching!
4. s quality of life/de OR menu planning/de OR food habits/de OR feeding behavior/de OR quality of health care/de OR compliance/ti,ab OR adherence/ti,ab OR motivation/ti,ab,de
5. s achievement/de OR motivation/de OR directive counseling/de OR counseling/de OR psychology, applied/de OR psychology, educational/de OR learning/de OR child guidance/de
6. s adaptation, psychological/de OR attitude/de OR attitude of health personnel/de OR professional-patient relations! OR attitude to health!
7. s health promotion/de OR decision making! OR risk reduction behavior/de OR early(w)intervention/de OR intervention/ti,ab OR interventions/ti,ab OR data collection/de
8. s diet, protein-restricted(l)methods OR diet, protein-restricted(l)trends OR diet, protein-restricted(l)psychology OR diet, protein-restricted(l)standards OR diet, protein-restricted(l)utilization
9. s health surveys/de OR nutrition assessment! OR Behavioral Risk Factor Surveillance System/de OR interviews! OR questionnaire?/ti,ab,de
10. s guideline adherence/de OR evaluation studies/de OR “outcome assessment (health care)” OR “process assessment (health care)” OR food labeling/de
11. c 1 OR 2 OR 3 OR 4 OR 5 OR 6 OR 7 OR 8 OR 9 OR 10
12. s celiac disease(l)diet therapy
13. c 11 AND 12
14. s triticum(l)adverse effects OR wheat hypersensitivity/de OR gluten(n2)withdraw? OR gluten(l)adverse effects OR gliadin(l)adverse effects OR gluten(w)free
15. s diet OR dietary OR diets OR nutrition OR nutritional
16. c 14 AND 15
17. c 13 OR 16
18. s s17/human
19. s s18/eng

[underlined: Part 2]

1. s food labeling/de
2. s celiac OR coeliac OR triticum OR wheat hypersensitivity/de OR gluten OR gliadin OR celiac disease/de
3. c 1 and 2
4. s s3/human
5. s s4/eng

EMBASE on DIALOG

1. s celiac???(w)disease OR coeliac???(w)disease OR celiac(w)sprue OR coeliac(w)sprue OR celiac(w)syndrome OR coeliac(w)syndrome OR celiac(w)syndrome
2. s celiacs OR coeliacs OR celiac disease/de
3. s silent(w)celiac OR silent(w)coeliac OR asymptomatic(w)celiac OR asymptomatic(w)coeliac OR undetected(n3)(celiac OR coeliac)
4. s subclinical(w)celiac OR subclinical(w)coeliac OR sub(w)clinical(w)celiac OR sub(w)clinical(w)coeliac OR undiagnosed(n3)celiac OR undiagnosed(n3)coeliac
5. s nontropical(w)sprue OR non(w)tropical(w)sprue OR endemic(w)sprue
6. s gluten(n3)enteropath? OR gluten(n3)sensitiv? OR gluten(n3)hypersensitive? OR gluten(n3)intoleran? OR glutenin??(n3)hypersensitiv? OR glutenin??(n3) sensitiv? OR glutenin??(n3)intoleran?
7. s gliadin(n3)hypersentitiv? OR gliadin(n3)intoleran?
8. s wheat(n3)hypersensitive? OR wheat(n3)intoleran? OR wheat allergy/de
9. s (wheat OR triticum OR gluten) AND (hypersensitivity/de OR food allergy/de)
10. c 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11. s diet restriction/de OR gluten(w)free(w)diet?? OR diet therapy/de OR diet?(w)intervention OR therapeutic(w)diet?? OR diet OR dietary OR diets OR nutrition OR nutritional OR dietary(w) restriction?? OR dietary(n3)guideline??
12. s intervention??/ti,ab,de OR feeding behavior/de OR gluten(w)free(w)food?/ti,ab OR nutritional intolerance/de
13. c 11 OR 12
14. c 10 AND 13
15. s health behavior/de OR illness behavior/de OR adaptive behavior/de OR behavior modification/de OR patient attitude/de OR patient compliance/de OR patient education/de OR patient guidance/de OR patient counseling/de
16. s quality of life/de OR coping(w)behavior/ti,ab OR adjustment??/ti,ab,de OR decision making/de OR early(w)intervention/ti,ab,de OR compliance/ti,ab OR adherence/ti,ab OR motivation/ti,ab,de OR coping behavior/de OR coping/ti,ab,de
17. s psychosocial(n3)aspect?? OR habit??/ti,ab,de OR attitude??/ ti,ab,de OR psychologic test /de OR counsel?/ti,ab,de OR psychological factor/de OR psycholog?/ti,ab,de
18. c 15 OR 16 OR 17
19. c 14 AND 18
20. s s19/human, eng

CAB and AGRICOLA on DIALOG

1. s celiac???(w)disease OR coeliac???(w)disease OR celiac(w)sprue OR coeliac(w)sprue OR celiac(w)syndrome OR coeliac(w)syndrome OR celiac(w)syndrome
2. s celiacs OR coeliacs OR celiac syndrome/de
3. s silent(w)celiac OR silent(w)coeliac OR asymptomatic(w)celiac OR asymptomatic(w)coeliac OR undetected(n3)(celiac OR coeliac)
4. s subclinical(w)celiac OR subclinical(w)coeliac OR sub(w)clinical(w)celiac OR sub(w)clinical(w)coeliac OR undiagnosed(n3)celiac OR undiagnosed(n3)coeliac
5. s nontropical(w)sprue OR non(w)tropical(w)sprue OR endemic(w)sprue
6. s gluten(n3)enteropath? OR gluten(n3)sensitiv? OR gluten(n3)hypersensitive? OR gluten(n3)intoleran? OR glutenin??(n3)hypersensitiv? OR glutenin??(n3) sensitiv? OR glutenin??(n3)intoleran?
7. s gliadin(n3)hypersentitiv? OR gliadin(n3)intoleran?
8. s wheat(n3)hypersensitive? OR wheat(n3)intoleran?
9. s (wheat OR triticum OR gluten) AND (hypersensitivity/de OR food allergies/de)
10. c 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11. s gluten(w)free(w)diet?? OR diet treatment/de OR diet?(w)intervention OR therapeutic diets/de OR diet OR dietary OR diets OR nutrition OR nutritional
12. s dietary(w)restriction?? OR dietary(n3)guideline?? OR intervention??/ti,ab,de OR feeding behavior/de OR gluten(w)free(w)food?/ti,ab OR
13. c 11 OR 12
14. c 10 AND 13
15. s behavior modification/de OR patient compliance/de OR patient education/de
16. s quality of life/de OR coping(w)behavior/ti,ab OR adjustment??/ti,ab,de OR decision making/de OR early(w)intervention/ti,ab,de OR compliance/ti,ab OR adherence/ti,ab OR motivation/ti,ab,de OR coping/ti,ab
17. s psychosocial(n3)aspect?? OR habit??/ti,ab,de OR attitude??/ ti,ab,de OR counsel?/ti,ab,de OR psychological factors/de OR psycholog?/ti,ab,de
18. c 15 OR 16 OR 17
19. c 14 AND 18
20. s s19/human
21. s s20/eng

PsycInfo on DIALOG

1. s celiac???(w)disease OR coeliac???(w)disease OR celiac(w)sprue OR coeliac(w)sprue OR celiac(w)syndrome OR coeliac(w)syndrome OR celiac(w)syndrome
2. s celiacs OR coeliacs
3. s silent(w)celiac OR silent(w)coeliac OR asymptomatic(w)celiac OR asymptomatic(w)coeliac OR undetected(n3)(celiac OR coeliac)
4. s subclinical(w)celiac OR subclinical(w)coeliac OR sub(w)clinical(w)celiac OR sub(w)clinical(w)coeliac OR undiagnosed(n3)celiac OR undiagnosed(n3)coeliac
5. s nontropical(w)sprue OR non(w)tropical(w)sprue OR endemic(w)sprue
6. s gluten(n3)enteropath? OR gluten(n3)sensitiv? OR gluten(n3)hypersensitive? OR gluten(n3)intoleran? OR glutenin??(n3)hypersensitiv? OR glutenin??(n3) sensitiv? OR glutenin??(n3)intoleran?
7. s gliadin(n3)hypersentitiv? OR gliadin(n3)intoleran?
8. s wheat(n3)hypersensitive? OR wheat(n3)intoleran? OR wheat(n3)(allergy OR allergies)
9. s (wheat OR triticum OR gluten) AND food allergies/de
10. c 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9
11. s gluten(w)free(w)diet?? OR diet?(w)intervention OR therapeutic(w)diet?? OR diet OR dietary OR diets OR nutrition OR nutritional OR dietary(w)restriction?? OR dietary(n3)guideline??
12. s intervention??/ti,ab OR gluten(w)free(w)food?/ti,ab
13. c 11 OR 12
14. c 10 AND 13
15. s health behavior/de OR illness behavior/de OR adaptive behavior/de OR behavior modification/de
16. s quality of life/de OR coping(w)behavior/ti,ab OR adjustment??/ti,ab,de OR decision making/de OR early(w)intervention/ti,ab,de OR compliance/ti,ab OR adherence/ti,ab OR motivation/ti,ab,de OR coping behavior/de OR coping/ti,ab
17. s psychosocial(n3)aspect?? OR habit??/ti,ab,de OR attitude??/ti,ab,de OR counsel?/ti,ab,de OR psycholog?/ti,ab,de
18. c 15 OR 16 OR 17
19. c 14 AND 18
20. s s19/human
21. s s20/eng

Sociological Abstracts at CAB

Limits set to English

1. celiac (KW) OR celiacs (KW) OR coeliac (KW) OR coeliacs (KW)
2. wheat (KW) OR food (DE) OR foods (kw) OR gluten* (KW) OR gliadin*
3. allergy (KW) OR allergies (KW) OR hypersensitive* (KW) OR intoleran* (KW) OR sensitive* (KW)
4. feeding practices (DE) OR feeding (DE)
5. diet (DE) OR nutrition (DE)
6. diet (KW) OR diets(KW) OR nutrition (KW)OR nutritional (KW)
7. 2 AND 3
8. 4 OR 5 OR 6
9. 1 AND 8
10. 7 AND 8
11. 9 OR 10