# Appendix L. Listing of Excluded Studies

### Objective 1 - Sensitivity and Specificity of Tests for CD

Abdulkarim A S, Murray J A. Review article: The diagnosis of coeliac disease. Alimentary Pharmacology & Therapeutics. 2003;17(8):987-995. Not sensitivity or specificity of an identified test. [pmid: 12694080].
Abdulkarim Ahmad S, Burgart Lawrence J, See Jacalyn, et al. Etiology of nonresponsive celiac disease: results of a systematic approach. American Journal of Gastroenterology. 2002;97(8):2016-2021. Not sensitivity or specificity of an identified test. [pmid: 12190170].
Abdullah A M. Aetiology of chronic diarrhoea in children: Experience at King Khalid University Hospital, Riyadh, Saudi Arabia. Ann Trop Paediatr. 1994;14(2):111-117. Not sensitivity or specificity of an identified test. [pmid: 7521625].
Abdullah A M, Elrab M G, Al Herbish A, et al. Serum antigliadin antibody as a marker of coeliac disease in children with chronic diarrhoea in Saudi Arabia. Med Sci Res. 1994;22(3):229. Not sensitivity or specificity of an identified test.
Abe K K, Michinaga I, Hiratsuka T, et al. Association of DQB1(*)0302 alloantigens in Japanese pediatric patients with steroid-sensitive nephrotic syndrome. Nephron. 1995;70(1):28-34. Not sensitivity or specificity of an identified test. [pmid: 7617114].
Abele M, Burk K, Schols L, et al. The aetiology of sporadic adult-onset ataxia. Brain. 2002;125(Pt 5):961-968. Not sensitivity or specificity of an identified test. [pmid: 11960886].
Abele M, Schols L, Schwartz S, et al. Prevalence of antigliadin antibodies in ataxia patients. Neurology. 2003;60(10):1674-1675. Not sensitivity or specificity of an identified test. [pmid: 12771263].
Abenoza P, Lillemoe T. CD34 and factor XIIIa in the differential diagnosis of dermatofibroma and dermatofibrosarcoma protuberans. American Journal of Dermatopathology. 1993;15(5):429-434. Not sensitivity or specificity of an identified test. [pmid: 7694515].
Ablin R J, Whyard T C. Identification and possible biological relevance of spermatozoal transglutaminase. Experientia. 1991;47(3):277-279. Not sensitivity or specificity of an identified test. [pmid: 1672655].
Acerini C L, Ahmed M L, Ross K M, et al. Coeliac disease in children and adolescents with IDDM: clinical characteristics and response to gluten-free diet. Diabetic Medicine - a Journal of the British Diabetic Association. 1998;15(1):38-44. Not sensitivity or specificity of an identified test. [pmid: 9472862].
Achyuthan K E, Goodell R J, Kennedye J R, et al. Immunochemical analyses of human plasma fibronectin-cytosolic transglutaminase interactions. Journal of Immunological Methods. 1995;180(1):69-79. Not sensitivity or specificity of an identified test. [pmid: 7534805].
Achyuthan K E, Slaughter T F, Santiago M A, et al. Factor XIIIa-derived peptides inhibit transglutaminase activity. Localization of substrate recognition sites. Journal of Biological Chemistry. 1993;268(28):21284-21292. Not sensitivity or specificity of an identified test. [pmid: 8104938].
Ackerman Z, Eliakim R, Stalnikowicz R, et al. Role of small bowel biopsy in the endoscopic evaluation of adults with iron deficiency anemia. American Journal of Gastroenterology. 1996;91(10):2099-2102. Not sensitivity or specificity of an identified test. [pmid: 8855729].
Adam Gregory C, Sorensen Erik J, Cravatt Benjamin F. Trifunctional chemical probes for the consolidated detection and identification of enzyme activities from complex proteomes. Molecular & Cellular Proteomics - Mcp. 2002;1(10):828-835. Not sensitivity or specificity of an identified test. [pmid: 12438565].
Adams E, Basten A, Rodda S, et al. Human T-cell clones to the 70-kilodalton heat shock protein of Mycobacterium leprae define mycobacterium-specific epitopes rather than shared epitopes. Infect Immun. 1997;65(3):1061-1070. Not sensitivity or specificity of an identified test. [pmid: 9038316]. [pmcid: 175088].
Adany R, Glukhova M A, Kabakov A Y, et al. Characterisation of connective tissue cells containing factor XIII subunit a. Journal of Clinical Pathology. 1988;41(1):49-56. Not sensitivity or specificity of an identified test. [pmid: 2893813]. [pmcid: 1141335].
Adini A, Krugliak M, Ginsburg H, et al. Transglutaminase in Plasmodium parasites: Activity and putative role in oocysts and blood stages. Mol Biochem Parasitol. 2001;117(2):161-168. Not sensitivity or specificity of an identified test. [pmid: 11606226].
Adleff V, Racz K, Szende B, et al. Coexpression of p53 and tissue transglutaminase genes in human normal and pathologic adrenal tissues. Journal of Steroid Biochemistry and Molecular Biology. 1998;66(12):27-33. Not sensitivity or specificity of an identified test. [pmid: 9712408].
Aeschlimann D, Thomazy V. Protein crosslinking in assembly and remodelling of extracellular matrices: the role of transglutaminases. Connective Tissue Research. 2000;41(1):1-27. Not sensitivity or specificity of an identified test. [pmid: 10826705].
Aeschlimann D, Koeller M K, Allen-Hoffmann B L, et al. Isolation of a cDNA encoding a novel member of the transglutaminase gene family from human keratinocytes. Detection and identification of transglutaminase gene products based on reverse transcription-polymerase chain reaction with degenerate primers. Journal of Biological Chemistry. 1998;273(6):3452-3460. Not sensitivity or specificity of an identified test. [pmid: 9452468].
Aeschlimann D, Mosher D, Paulsson M. Tissue transglutaminase and factor XIII in cartilage and bone remodeling. Semin Thromb Hemost. 1996;22(5):437-443. Not sensitivity or specificity of an identified test. [pmid: 8989828].
Aeschlimann D, Wetterwald A, Fleisch H, et al. Expression of tissue transglutaminase in skeletal tissues correlates with events of terminal differentiation of chondrocytes. J Cell Biol. 1993;120(6):1461-1470. Not sensitivity or specificity of an identified test. [pmid: 8095503].
Agardh D, Agardh E, Landin-Olsson M, et al. Inverse relationship between GAD65 antibody levels and severe retinopathy in younger type 1 diabetic patients. Diabetes Res Clin Pract. 1998;40(1):9-14. Not sensitivity or specificity of an identified test. [pmid: 9699085].
Agardh D, Gaur L K, Agardh E, et al. HLA-DQB1*0201/0302 is associated with severe retinopathy in patients with IDDM. Diabetologia. 1996;39(11):1313-1317. Not sensitivity or specificity of an identified test. [pmid: 8932997].
Agardh D, Nilsson A, Carlsson A, et al. Tissue transglutaminase autoantibodies and human leucocyte antigen in Down Syndrome patients with coeliac disease. Acta Paediatrica (Oslo, Norway - 1992). 2002;91(1):34-38. Improper control group. [pmid: 11883815].
Agardh D, Nilsson A, Tuomi T, et al. Prediction of silent celiac disease at diagnosis of childhood type 1 diabetes by tissue transglutaminase autoantibodies and HLA. Pediatr Diabetes. 2001;2(2):58-65. Not sensitivity or specificity of an identified test. [pmid: 15016199].
Agardh Daniel, Borulf Stefan, Lernmark Ake, et al. Tissue transglutaminase immunoglobulin isotypes in children with untreated and treated celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 2003;36(1):77-82. Improper control group. [pmid: 12500000].
Agrawal S, Gupta A, Yachha S K, et al. Association of human leucocyte-DR and DQ antigens in coeliac disease: a family study. Journal of Gastroenterology and Hepatology. 2000;15(7):771-774. Improper control group. [pmid: 10937683].
Agreus L, Svardsudd K, Tibblin G, et al. Endomysium antibodies are superior to gliadin antibodies in screening for coeliac disease in patients presenting supposed functional gastrointestinal symptoms. Scandinavian Journal of Primary Health Care. 2000;18(2):105-110. Improper control group. [pmid: 10944065].
Aguirre J M, Rodriguez R, Oribe D, et al. Dental enamel defects in celiac patients. Oral Surgery, Oral Medicine, Oral Pathology, Oral Radiology, and Endodontics. 1997;84(6):646-650. Not sensitivity or specificity of an identified test. [pmid: 9431534].
Ahmed A R, Mohimen A, Yunis E J, et al. Linkage of pemphigus vulgaris antibody to the major histocompatibility complex in healthy relatives of patients. J Exp Med. 1993;177(2):419-424. Not sensitivity or specificity of an identified test. [pmid: 8426112].
Ahmed A R, Yunis J J, Marcus-Bagley D, et al. Major histocompatibility complex susceptibility genes for dermatitis herpetiformis compared with those for gluten-sensitive enteropathy. Journal of Experimental Medicine. 1993;178(6):2067-2075. Not sensitivity or specificity of an identified test. [pmid: 8245782].
Aho H J, Ping W, Soderstrom K O, et al. Acid cysteine proteinase inhibitor in cutaneous lymphocytic infiltrates. American Journal of Dermatopathology. 1995;17(2):115-125. Not sensitivity or specificity of an identified test. [pmid: 8600775].
Ahvazi Bijan, Kim Hee, Chul Kee, et al. Three-dimensional structure of the human transglutaminase 3 enzyme: binding of calcium ions changes structure for activation. Embo Journal. 2002;21(9):2055-2067. Not sensitivity or specificity of an identified test. [pmid: 11980702]. [pmcid: 125988].
Aiba S, Tabata N, Ohtani H, et al. CD34+ spindle-shaped cells selectively disappear from the skin lesion of scleroderma. Archives of Dermatology. 1994;130(5):593-597. Not sensitivity or specificity of an identified test. [pmid: 7513987].
Aine L. Coeliac-type permanent-tooth enamel defects. Ann Med. 1996;28(1):9-12. Not sensitivity or specificity of an identified test. [pmid: 8932499].
Aine L, Maki M, Reunala T. Coeliac-type dental enamel defects in patients with dermatitis herpetiformis. Acta Dermato-Venereologica. 1992;72(1):25-27. Not sensitivity or specificity of an identified test. [pmid: 1350136].
Akagi Atsushi, Tajima Shingo, Ishibashi Akira, et al. Type XVI collagen is expressed in factor XIIIa+ monocyte-derived dermal dendrocytes and constitutes a potential substrate for factor XIIIa. Journal of Investigative Dermatology. 2002;118(2):267-274. Not sensitivity or specificity of an identified test. [pmid: 11841543].
Akimov S S, Belkin A M. Cell surface tissue transglutaminase is involved in adhesion and migration of monocytic cells on fibronectin. Blood. 2001;98(5):1567-1576. Not sensitivity or specificity of an identified test. [pmid: 11520809].
Akimov S S, Belkin A M. Cell-surface transglutaminase promotes fibronectin assembly via interaction with the gelatin-binding domain of fibronectin: A role in TGF-beta-dependent matrix deposition. Journal of Cell Science. 2001;114(16):2989-3000. Not sensitivity or specificity of an identified test. [pmid: 11686302].
Akimov S S, Krylov D, Fleischman L F, et al. Tissue transglutaminase is an integrin-binding adhesion coreceptor for fibronectin. Journal of Cell Biology. 2000;148(4):825-838. Not sensitivity or specificity of an identified test. [pmid: 10684262].
Akiyama H, Kondo H, Ikeda K, et al. Immunohistochemical detection of coagulation factor XIIIa in postmortem human brain tissue. Neuroscience Letters. 1995;202(12):29-32. Not sensitivity or specificity of an identified test. [pmid: 8787823].
Akiyama M, Matsuo I, Shimizu H. Formation of cornified cell envelope in human hair follicle development. British Journal of Dermatology. 2002;146(6):968-976. Not sensitivity or specificity of an identified test. [pmid: 12072064].
Akiyama M, Smith L T, Yoneda K, et al. Transglutaminase and major cornified cell envelope precursor proteins, loricrin, small proline-rich proteins 1 and 2, and involucrin are coordinately expressed in the sites defined to form hair canal in developing human hair follicle. Exp Dermatol. 1999;8(4):313-314. Not sensitivity or specificity of an identified test. [pmid: 10439243].
Aktay A N, Lee P C, Kumar V, et al. The prevalence and clinical characteristics of celiac disease in juvenile diabetes in Wisconsin. Journal of Pediatric Gastroenterology and Nutrition. 2001;33(4):462-465. Not sensitivity or specificity of an identified test. [pmid: 11698764].
Al Ashwal A A, Shabib S M, Sakati N A, et al. Prevalence and characteristics of celiac disease in type I diabetes mellitus in Saudi Arabia. Saudi Med J. 2003;24(10):1113-1115. Not sensitivity or specificity of an identified test. [pmid: 14578980].
Al Attas R A. How common is celiac disease in Eastern Saudi Arabia?. Ann Saudi Med. 2002;22(56):315-319. Not sensitivity or specificity of an identified test. [pmid: 17146251].
Al Bayatti S M. Etiology of chronic diarrhea. Saudi Med J. 2002;23(6):675-679. Not sensitivity or specificity of an identified test. [pmid: 12070546].
al Bayaty H F, Aldred M J, Walker D M, et al. Salivary and serum antibodies to gliadin in the diagnosis of celiac disease. Journal of Oral Pathology & Medicine - Official Publication of the International Association of Oral Pathologists and the American Academy of Oral Pathology. 1989;18(10):578-581. Serology <1990. [pmid: 2621654].
al Dawoud A, Nakshabendi I, Foulis A, et al. Immunohistochemical analysis of mucosal gamma-interferon production in coeliac disease. Gut. 1992;33(11):1482-1486. Not sensitivity or specificity of an identified test. [pmid: 1452072]. [pmcid: 1379532].
Al Harbi S, Fouad F, Kaaba S A. The first HLA anthropological study in the Kuwaiti population. Eur J Immunogenet. 1994;21(5):295-300. Not sensitivity or specificity of an identified test. [pmid: 9098439].
Al Mofleh I A, Jessen K, Al-Rashed Al-Hmaid, et al. Pediatric esophagogastroduodenoscopy in Saudi Arabia. Ann Saudi Med. 1989;9(1):32-35. Not sensitivity or specificity of an identified test.
al Tawaty A I, Elbargathy S M. Coeliac disease in north-eastern Libya. Annals of Tropical Paediatrics. 1998;18(1):27-30. Not sensitivity or specificity of an identified test. [pmid: 9691998].
Albert E D, Harms K, Wank R, et al. Segregation analysis of HL-A antigens and haplotypes in 50 families of patients with coeliac disease. Transplantation Proceedings. 1973;5(4):1785-1789. Not sensitivity or specificity of an identified test. [pmid: 4775642].
Aldener-Cannava A, Olerup O. HLA-DOB1 "low-resolution' typing by PCR amplification with sequence-specific primers (PCR-SSP). European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1994;21(6):447-455. Not sensitivity or specificity of an identified test. [pmid: 9098454].
Aldersley M A, Hamlin P J, Jones P F, et al. No polymorphism in the tissue transglutaminase gene detected in coeliac disease patients. Scandinavian Journal of Gastroenterology. 2000;35(1):61-63. Not sensitivity or specificity of an identified test. [pmid: 10672836].
Aleanzi M, Demonte A M, Esper C, et al. Celiac disease: antibody recognition against native and selectively deamidated gliadin peptides. Clinical Chemistry. 2001;47(11):2023-2028. Not sensitivity or specificity of an identified test. [pmid: 11673371].
Alfonso P, Soto C, Albar J P, et al. Beta structure motif recognition by anti-gliadin antibodies in coeliac disease. Febs Letters. 1998;427(1):36-40. Not sensitivity or specificity of an identified test. [pmid: 9613595].
Alfos S, Boucheron C, Pallet V, et al. A retinoic acid receptor antagonist suppresses brain retinoic acid receptor overexpression and reverses a working memory deficit induced by chronic ethanol consumption in mice. Alcohol Clin Exp Res. 2001;25(10):1506-1514. Not sensitivity or specificity of an identified test. [pmid: 11696672].
Alfos S, Higueret P, Pallet V, et al. Chronic ethanol consumption increases the amount of mRNA for retinoic acid and triiodothyronine receptors in mouse brain. Neurosci Lett. 1996;206(23):73-76. Not sensitivity or specificity of an identified test. [pmid: 8710190].
Alkushi A, Irving J, Hsu F, et al. Immunoprofile of cervical and endometrial adenocarcinomas using a tissue microarray. Virchows Arch. 2003;442(3):271-277. Not sensitivity or specificity of an identified test. [pmid: 12647218].
Alper C A, Fleischnick E, Awdeh Z, et al. Extended major histocompatibility complex haplotypes in patients with gluten-sensitive enteropathy. Journal of Clinical Investigation. 1987;79(1):251-256. Not sensitivity or specificity of an identified test. [pmid: 3793924]. [pmcid: 424034].
Alpers D H. Another piece to the celiac puzzle. Journal of Pediatric Gastroenterology and Nutrition. 1987;6(1):5-7. Not sensitivity or specificity of an identified test. [pmid: 3794933].
Alsaigh N, Odze R, Goldman H, et al. Gastric and esophageal intraepithelial lymphocytes in pediatric celiac disease. American Journal of Surgical Pathology. 1996;20(7):865-870. Not sensitivity or specificity of an identified test. [pmid: 8669535].
Altmann D M. HLA-DQ associations with autoimmune disease. Autoimmunity. 1992;14(1):79-83. Not sensitivity or specificity of an identified test. [pmid: 1299350].
Altmann D M, Sansom D, Marsh S G. What is the basis for HLA-DQ associations with autoimmune disease?. Immunology Today. 1991;12(8):267-270. Not sensitivity or specificity of an identified test. [pmid: 1910448].
Altuntas B, Kansu A, Girgin N. Hepatic damage in gluten sensitive enteropathy. Acta Paediatrica Japonica 1998;Overseas Edition; 40(6):597–599. Not sensitivity or specificity of an identified test
Altuntas cedil, Filik B, Ensari A, et al. Can zinc deficiency be used as a marker for the diagnosis of celiac disease in Turkish children with short stature?. Pediatr Int. 2000;42(6):682-684. Not sensitivity or specificity of an identified test. [pmid: 11192528].
Alvarez D, Vazquez H, Bai J C, et al. Superior mesenteric artery blood flow in celiac disease. Digestive Diseases and Sciences. 1993;38(7):1175-1182. Not sensitivity or specificity of an identified test. [pmid: 8325179].
Amann E, Abel K J, Grundmann U et al. Synthesis of human factor XIIIa in bacterial cells. Behring Institute Mitteilungen 1988;(82):35–42. Not sensitivity or specificity of an identified test
Amanzadeh A, Shokrgozar M-A, Samadi-Bahrami Z, et al. Frequency analysis of HLA antigens in Iranian patients with common variable immunodeficiency. Arch Iran Med. 2003;6(1):16-22. Not sensitivity or specificity of an identified test.
Amara W, Husebekk A. Improved method for serological testing in celiac disease--IgA anti-endomysium antibody test: a comparison between monkey oesophagus and human umbilical cord as substrate in indirect immunofluorescence test. Scandinavian Journal of Clinical and Laboratory Investigation. 1998;58(7):547-554. Not sensitivity or specificity of an identified test. [pmid: 9890337].
Ambrus A, Fesus L. Polyethylene glycol enhanced refolding of the recombinant human tissue transglutaminase. Preparative Biochemistry & Biotechnology. 2001;31(1):59-70. Not sensitivity or specificity of an identified test. [pmid: 11321164].
Ambrus A, Banyai I, Weiss M S, et al. Calcium binding of transglutaminases: a 43Ca NMR study combined with surface polarity analysis. Journal of Biomolecular Structure & Dynamics. 2001;19(1):59-74. Not sensitivity or specificity of an identified test. [pmid: 11565852].
Amendola A, Gougeon M L, Poccia F, et al. Induction of “tissue” transglutaminase in HIV pathogenesis: evidence for high rate of apoptosis of CD4+ T lymphocytes and accessory cells in lymphoid tissues. Proceedings of the National Academy of Sciences of the United States of America. 1996;93(20):11057-11062. Not sensitivity or specificity of an identified test. [pmid: 8855308]. [pmcid: 38283].
Amendola A, Lombardi G, Oliverio S, et al. HIV-1 gp120-dependent induction of apoptosis in antigen-specific human T cell clones is characterized by ‘tissue’ transglutaminase expression and prevented by cyclosporin A. Febs Lett. 1994;339(3):258-264. Not sensitivity or specificity of an identified test. [pmid: 7906657].
Amendola A, Rodolfo C, Di Caro A et al. “Tissue” transglutaminase expression in HIV-infected cells: an enzyme with an antiviral effect?. Annals of the New York Academy of Sciences 2001;946108–120. Not sensitivity or specificity of an identified test
Amendola Alessandra, Fesus Laszlo, Piacentini Mauro, et al. “Tissue” transglutaminase in AIDS. Journal of Immunological Methods. 2002;265(12):145-159. Not sensitivity or specificity of an identified test. [pmid: 12072185].
Ament M E. Diagnosis and treatment of giardiasis. Journal of Pediatrics. 1972;80(4):633-637. Not sensitivity or specificity of an identified test. [pmid: 5015072].
Ament M E, Ochs H D. Gastrointestinal manifestations of chronic granulomatous disease. New England Journal of Medicine. 1973;288(8):382-387. Not sensitivity or specificity of an identified test. [pmid: 4684040].
Ament M E, Perera D R, Esther L J. Sucrase-isomaltase deficiency-a frequently misdiagnosed disease. Journal of Pediatrics. 1973;83(5):721-727. Not sensitivity or specificity of an identified test. [pmid: 4742566].
Amin M, Eckhardt T, Kapitza S et al. Correlation between tissue transglutaminase antibodies and endomysium antibodies as diagnostic markers of coeliac disease. Clinica Chimica Acta 1999;International Journal of Clinical Chemistry; 282(1–2):219–225. Not sensitivity or specificity of an identified test
Amoah J, Williams C, Long R G. Calmodulin content and activity in normal and coeliac duodenum. Gut. 1992;33(3):303-306. Not sensitivity or specificity of an identified test. [pmid: 1314761]. [pmcid: 1373816].
Amoroso A, Mazzola G, Canale L, et al. HLA in juvenile dermatitis herpetiformis: clinical heterogeneity correlated with DNA and serological polymorphism. J Immunogenet. 1990;17(3):195-206. Not sensitivity or specificity of an identified test. [pmid: 1979987].
Anand B S, Piris J, Truelove S C. The role of various cereals in coeliac disease. Quarterly Journal of Medicine. 1978;47(185):101-110. Not sensitivity or specificity of an identified test. [pmid: 674547].
Anand B S, Piris J, Jerrome D W, et al. The timing of histological damage following a single challenge with gluten in treated coeliac disease. Quarterly Journal of Medicine. 1981;50(197):83-94. Not sensitivity or specificity of an identified test. [pmid: 7267970].
Anantharaman V, Koonin E V, Aravind L. Peptide-N-glycanases and DNA repair proteins, Xp-C/Rad4, are, respectively, active and inactivated enzymes sharing a common transglutaminase fold. Human Molecular Genetics. 2001;10(16):1627-1630. Not sensitivity or specificity of an identified test. [pmid: 11487565].
Andersen K J, Schjonsby H, Skagen D W. Jejunal mucosal enzymes in untreated and treated coeliac disease. Scandinavian Journal of Gastroenterology. 1983;18(2):251-256. Not sensitivity or specificity of an identified test. [pmid: 6144177].
Andersen K J, Schjonsby H, Skagen D W, et al. Enzyme activities in jejunal biopsy samples from patients with adult coeliac disease with and without steatorrhoea. Scandinavian Journal of Gastroenterology. 1983;18(3):365-368. Not sensitivity or specificity of an identified test. [pmid: 6144177].
Anderson R P, Degano P, Godkin A J, et al. In vivo antigen challenge in celiac disease identifies a single transglutaminase-modified peptide as the dominant A-gliadin T-cell epitope. Nature Medicine. 2000;6(3):337-342. Not sensitivity or specificity of an identified test. [pmid: 10700238].
Andersson H, Bjorkman A C, Gillberg R, et al. Influence of the amount of dietary gluten on gastrointestinal morphology and function in dermatitis herpetiformis. Human Nutrition. Clinical Nutrition. 1984;38(4):279-285. Not sensitivity or specificity of an identified test. [pmid: 6469705].
Ando M, Tatematsu T, Kunii S, et al. Blockade effect of nerve growth factor on GM1 ganglioside-induced activation of transglutaminase in superior cervical sympathetic ganglia excised from adult rat. Neurosci Res. 1994;19(4):373-378. Not sensitivity or specificity of an identified test. [pmid: 7916448].
Ando Y, Imamura S, Owada M K, et al. Calcium-induced intracellular cross-linking of lipocortin I by tissue transglutaminase in A431 cells. Augmentation by membrane phospholipids. Journal of Biological Chemistry. 1991;266(2):1101-1108. Not sensitivity or specificity of an identified test. [pmid: 1670773].
Ando Y, Imamura S, Owada M K, et al. Cross-linking of lipocortin I and enhancement of its Ca2+ sensitivity by tissue transglutaminase. Biochemical and Biophysical Research Communications. 1989;163(2):944-951. Not sensitivity or specificity of an identified test. [pmid: 2571332].
Andria G, Cucchiara S, De Vizia B. Brush border and cytosol peptidase activities of human small intestine in normal subjects and celiac patients. Pediatric Research. 1980;14(6):812-818. Not sensitivity or specificity of an identified test. [pmid: 6995920].
Annibale B, Capurso G, Chistolini A, et al. Gastrointestinal causes of refractory iron deficiency anemia in patients without gastrointestinal symptoms. Am J Med. 2001;111(6):439-445. Not sensitivity or specificity of an identified test. [pmid: 11690568].
Annibale B, Lahner E, Chistolini A, et al. Endoscopic evaluation of the upper gastrointestinal tract is worthwhile in premenopausal women with iron-deficiency anaemia irrespective of menstrual flow. Scandinavian Journal of Gastroenterology. 2003;38(3):239-245. Not sensitivity or specificity of an identified test. [pmid: 12737437].
Annibale B, Severi C, Chistolini A, et al. Efficacy of gluten-free diet alone on recovery from iron deficiency anemia in adult celiac patients. American Journal of Gastroenterology. 2001;96(1):132-137. Not sensitivity or specificity of an identified test. [pmid: 11197242].
Annicchiarico-Petruzzelli M, Bernassola F, Lovat P E, et al. Apoptosis in neuroblastomas induced by interferon-gamma involves the CD95/CD95L pathway. Medical and Pediatric Oncology. 2001;36(1):115-117. Not sensitivity or specificity of an identified test. [pmid: 11464861].
Anonymous. Collagenous sprue. Lancet 1971;1(7701):692Not sensitivity or specificity of an identified test
Anonymous. Collagenous sprue. British Medical Journal 1971;2(753):65–66. Not sensitivity or specificity of an identified test
Anonymous. Giardia lamblia and coeliac disease. Lancet 1973;2(7821):138Not sensitivity or specificity of an identified test
Anonymous. The gut and dermatitis herpetiformis. British Medical Journal 1971;4(778):5Not sensitivity or specificity of an identified test
Anonymous. Medical grand rounds from the University of Alabama Medical Center. Southern Medical Journal 1969;62(1):65–70. Not sensitivity or specificity of an identified test
Anonymous. Dermatitis herpetiformis--the thin veneer?. Lancet 1978;2(8087):458–459. Not sensitivity or specificity of an identified test
Anonymous. Bird fancier's lung and jejunal villous atrophy. Med J Aust 1976;1(22):813–814. Not sensitivity or specificity of an identified test
Anonymous. A guide for patients. Pract Gastroenterol 2002;26(11):58–61. Not sensitivity or specificity of an identified test
Anonymous. Highly inheritable coeliac disease. Med Today 2002;3(7):15Not sensitivity or specificity of an identified test
Anonymous. Latent coeliac disease. Arch Dis Child 1990;65(10):1192Not sensitivity or specificity of an identified test
Anonymous. A new type intestinal lymphoma. J Clin Pathol Mol Pathol 2002;55(5):314Not sensitivity or specificity of an identified test
Anonymous. Oats safe for coeliac disease patients. Pharm J 2002;268(7185):200Not sensitivity or specificity of an identified test
Anonymous. On the pathogenesis of gluten sensitive enteropathy. Nutr Rev 1974;32(9):267–270. Not sensitivity or specificity of an identified test
Anonymous. PIR quiz. Pediatr Rev 2003;24(6):205–206. Not sensitivity or specificity of an identified test
Anstey A, Cerio R, Ramnarain N, et al. Desmoplastic malignant melanoma. An immunocytochemical study of 25 cases. American Journal of Dermatopathology. 1994;16(1):14-22. Not sensitivity or specificity of an identified test. [pmid: 7512798].
Anstey A, Wilkinson J D, Walshe M M. Dermatitis herpetiformis in monozygous twins--concordance for dermatitis herpetiformis and gluten-sensitive enteropathy. Clinical and Experimental Dermatology. 1991;16(1):51-52. Not sensitivity or specificity of an identified test. [pmid: 2025937].
Antonioli D A. Celiac disease: A progress report. Mod Pathol. 2003;16(4):342-346. Not sensitivity or specificity of an identified test. [pmid: 12692199].
Antonowicz I, Shwachman H, Sotoo I. Beta-galactosidase and beta-glucuronidase activities in intestinal mucosa of infants and children. Pediatrics. 1971;47(4):737-744. Not sensitivity or specificity of an identified test. [pmid: 5089761].
Antonyak M A, Singh U S, Lee D A, et al. Effects of tissue transglutaminase on retinoic acid-induced cellular differentiation and protection against apoptosis. Journal of Biological Chemistry. 2001;276(36):33582-33587. Not sensitivity or specificity of an identified test. [pmid: 11438548].
Antonyak Marc A, Boehm Jason E, Cerione Richard A. Phosphoinositide 3-kinase activity is required for retinoic acid-induced expression and activation of the tissue transglutaminase. Journal of Biological Chemistry. 2002;277(17):14712-14716. Not sensitivity or specificity of an identified test. [pmid: 11854287].
Aoun J P, Moukarbel N, Aftimos G. Value of duodenal endoscopic markers of villous atrophy. Le Journal Medical Libanais. The Lebanese Medical Journal. 2001;49(6):319-324. Not sensitivity or specificity of an identified test. [pmid: 12744633].
Appelt D M, Balin B J. The association of tissue transglutaminase with human recombinant tau results in the formation of insoluble filamentous structures. Brain Research. 1997;745(12):21-31. Not sensitivity or specificity of an identified test. [pmid: 9037390].
Appelt D M, Kopen G C, Boyne L J, et al. Localization of transglutaminase in hippocampal neurons: implications for Alzheimer's disease. Journal of Histochemistry and Cytochemistry - Official Journal of the Histochemistry Society. 1996;44(12):1421-1427. Not sensitivity or specificity of an identified test.
Applegate D, Steben L S, Hertzberg K M, et al. The alpha(E)C domain of human fibrinogen-420 is a stable and early plasmin cleavage product. Blood. 2000;95(7):2297-2303. Not sensitivity or specificity of an identified test. [pmid: 10733499].
Arai T, Michalski J P, McCombs C C, et al. T cell receptor gamma gene polymorphisms and class II human lymphocyte antigen genotypes in patients with celiac disease from the west of Ireland. American Journal of the Medical Sciences. 1995;309(3):171-178. Not sensitivity or specificity of an identified test. [pmid: 7879822].
Arany I, Evans T, Tyring S K. Tissue specific HPV expression and downregulation of local immune responses in condylomas from HIV seropositive individuals. Sexually Transmitted Infections. 1998;74(5):349-353. Not sensitivity or specificity of an identified test. [pmid: 10195031].
Arato A, Hacsek G, Savilahti E. Immunohistochemical findings in the jejunal mucosa of patients with coeliac disease. Scandinavian Journal of Gastroenterology.Supplement 1998;2283–10. Not sensitivity or specificity of an identified test
Arato A, Savilahti E, Tainio V M, et al. HLA-DR expression, natural killer cells and IgE containing cells in the jejunal mucosa of coeliac children. Gut. 1987;28(8):988-994. Not sensitivity or specificity of an identified test. [pmid: 3311907]. [pmcid: 1433137].
Arato Andras, Korner Anna, Veres Gabor, et al. Frequency of coeliac disease in Hungarian children with type 1 diabetes mellitus. European Journal of Pediatrics. 2002;162(1):1-5. Not sensitivity or specificity of an identified test. [pmid: 12486500].
Araya M, Henderson-Smart D. Letter: Coeliac disease: an undiagnosed disorder with important implications. Medical Journal of Australia. 1974;1(14):549. Not sensitivity or specificity of an identified test. [pmid: 4831751].
Araya M, Walker-Smith J A. Specificity of ultrastructural changes of small intestinal epithelium in early childhood. Archives of Disease in Childhood. 1975;50(11):844-855. Not sensitivity or specificity of an identified test. [pmid: 1211956].
Araya M, Mondragon A, Perez-Bravo F, et al. Celiac disease in a Chilean population carrying Amerindian traits. Journal of Pediatric Gastroenterology and Nutrition. 2000;31(4):381-386. Not sensitivity or specificity of an identified test. [pmid: 11045834].
Arellanes-Garcia L, Bautista N, Mora P, et al. HLA-DR is strongly associated with Vogt-Koyanagi-Harada disease in Mexican Mestizo patients. Ocul Immunol Inflamm. 1998;6(2):93-100. Not sensitivity or specificity of an identified test. [pmid: 9689639].
Arentz-Hansen E H, McAdam S N, Molberg O, et al. Production of a panel of recombinant gliadins for the characterisation of T cell reactivity in coeliac disease. Gut. 2000;46(1):46-51. Not sensitivity or specificity of an identified test. [pmid: 10601054]. [pmcid: 1727782].
Arentz-Hansen H, Korner R, Molberg O, et al. The intestinal T cell response to alpha-gliadin in adult celiac disease is focused on a single deamidated glutamine targeted by tissue transglutaminase. Journal of Experimental Medicine. 2000;191(4):603-612. Not sensitivity or specificity of an identified test. [pmid: 10684852].
Arentz-Hansen Helene, McAdam Stephen N, Molberg Oyvind, et al. Celiac lesion T cells recognize epitopes that cluster in regions of gliadins rich in proline residues. Gastroenterology. 2002;123(3):803-809. Not sensitivity or specificity of an identified test. [pmid: 12198706].
Argenyi Z B, Santa Cruz D, Bromley C. Comparative light-microscopic and immunohistochemical study of traumatic and palisaded encapsulated neuromas of the skin. American Journal of Dermatopathology. 1992;14(6):504-510. Not sensitivity or specificity of an identified test. [pmid: 1281969].
Arilla E, Hernandez M, Polanco I, et al. Modification of somatostatin content and binding in jejunum from celiac children. Journal of Pediatric Gastroenterology and Nutrition. 1987;6(2):228-233. Not sensitivity or specificity of an identified test. [pmid: 2891807].
Armes J, Gee D C, Macrae F A, et al. Collagenous colitis: jejunal and colorectal pathology. Journal of Clinical Pathology. 1992;45(9):784-787. Not sensitivity or specificity of an identified test. [pmid: 1401208]. [pmcid: 495104].
Arnaiz-Villena A, Benmamar D, Alvarez M, et al. HLA allele and haplotype frequencies in Algerians: Relatedness to Spaniards and Basques. Hum Immunol. 1995;43(4):259-268. Not sensitivity or specificity of an identified test. [pmid: 7499173].
Arnaiz-Villena A, Martinez-Laso J, Corell A, et al. Frequencies of HLA-A24 and HLA-DR4-DQ8 are increased and that of HLA-B blank is decreased in chronic toxic oil syndrome. Eur J Immunogenet. 1996;23(3):211-219. Not sensitivity or specificity of an identified test. [pmid: 8803534].
Arnason A, Skaftadottir I, Sigmundsson J, et al. The association between coeliac disease, dermatitis herpetiformis and certain HLA-antigens in Icelanders. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1994;21(6):457-460. Improper control group. [pmid: 9098455].
Arnason J A, Gudjonsson H, Freysdottir J, et al. Do adults with high gliadin antibody concentrations have subclinical gluten intolerance?. Gut. 1992;33(2):194-197. Not sensitivity or specificity of an identified test. [pmid: 1541415]. [pmcid: 1373929].
Arnaud-Battandier F, Cerf-Bensussan N, Amsellem R, et al. Increased HLA-DR expression by enterocytes in children with celiac disease. Gastroenterology. 1986;91(5):1206-1212. Not sensitivity or specificity of an identified test. [pmid: 3758613].
Arnaud-Battandier F, Schmitz J, Muller J Y, et al. HLA and gluten cytotoxicity in vitro. Gastroenterology. 1983;84(1):201. Not sensitivity or specificity of an identified test. [pmid: 6571710].
Arnett F C, Reveille J D, Moutsopoulos H M, et al. Ribosomal P autoantibodies in systemic lupus erythematosus: Frequencies in different ethnic groups and clinical and immunogenetic associations. Arthritis Rheum. 1996;39(11):1833-1839. Not sensitivity or specificity of an identified test. [pmid: 8912505].
Arnett F C, Targoff I N, Mimori T, et al. Interrelationship of major histocompatibility complex class II alleles and autoantibodies in four ethnic groups with various forms of myositis. Arthritis Rheum. 1996;39(9):1507-1518. Not sensitivity or specificity of an identified test. [pmid: 8814062].
Arnett F C, Thiagarajan P, Ahn C, et al. Associations of anti-betainf 2-glycoprotein I autoantibodies with HLA class II alleles in three ethnic groups. Arthritis Rheum. 1999;42(2):268-274. Not sensitivity or specificity of an identified test. [pmid: 10366111].
Arranz E, Ferguson A. Intestinal antibody pattern of celiac disease: occurrence in patients with normal jejunal biopsy histology. Gastroenterology. 1993;104(5):1263-1272. Not sensitivity or specificity of an identified test. [pmid: 8482440].
Arranz E, Ferguson A. Jejunal fluid antibodies and mucosal gamma/delta IEL in latent and potential coeliac disease. Adv Exp Med Biol. 1995;371(B):1345-1348. Not sensitivity or specificity of an identified test. [pmid: 7502814].
Arranz E, Bode J, Kingstone K, et al. Intestinal antibody pattern of coeliac disease: association with gamma/delta T cell receptor expression by intraepithelial lymphocytes, and other indices of potential coeliac disease. Gut. 1994;35(4):476-482. Not sensitivity or specificity of an identified test. [pmid: 8174984]. [pmcid: 1374795].
Arranz E, Telleria J J, Sanz A, et al. HLA-DQA1*0501 and DQB1*02 homozygosity and disease susceptibility in Spanish coeliac patients. Experimental and Clinical Immunogenetics. 1997;14(4):286-290. Improper control group. [pmid: 9523165].
Arrese Estrada J, Pierard G E. Dendrocytes in verruga peruana and bacillary angiomatosis. Dermatology (Basel, Switzerland). 1992;184(1):22-25. Not sensitivity or specificity of an identified test. [pmid: 1477433].
Arroyo H A, De Rosa S, Ruggieri V, et al. Epilepsy, occipital calcifications, and oligosymptomatic celiac disease in childhood. J Child Neurol. 2002;17(11):800-806. Not sensitivity or specificity of an identified test. [pmid: 12585717].
Arthur A B, Clayton B E, Cottom D G, et al. Importance of disaccharide intolerance in the treatment of coeliac disease. Lancet. 1966;1(7430):172-174. Not sensitivity or specificity of an identified test. [pmid: 4159096].
Artuc Metin, Steckelings U, Muscha Grutzkau, et al. A long-term coculture model for the study of mast cell-keratinocyte interactions. Journal of Investigative Dermatology. 2002;119(2):411-415. Not sensitivity or specificity of an identified test. [pmid: 12190864].
Arvola Taina, Mustalahti Kirsi, Saha Marja, et al. Celiac disease, thyrotoxicosis, and autoimmune hepatitis in a child. Journal of Pediatric Gastroenterology and Nutrition. 2002;35(1):90-92. Not sensitivity or specificity of an identified test. [pmid: 12142818].
Ascher H, Holm K, Kristiansson B, et al. Different features of coeliac disease in two neighbouring countries. Archives of Disease in Childhood. 1993;69(3):375-380. Not sensitivity or specificity of an identified test. [pmid: 8215549].
Ascher H, Krantz I, Kristiansson B. Increasing incidence of coeliac disease in Sweden. Arch Dis Child. 1991;66(5):608-611. Not sensitivity or specificity of an identified test. [pmid: 2039251].
Ascher H, Kristiansson B, Krasilnikoff Collin, et al. The highest incidence of celiac disease in Europe: The Swedish experience. Journal of Pediatric Gastroenterology and Nutrition. 1997;24(5):S3-S6. Not sensitivity or specificity of an identified test. [pmid: 9161966].
Ashabani A, Errabtea H, Shapan A, et al. Serologic markers of untreated celiac disease in Libyan children: antigliadin, antitransglutaminase, antiendomysial, and anticalreticulin antibodies. Journal of Pediatric Gastroenterology and Nutrition. 2001;33(3):276-282. Improper control group. [pmid: 11593122].
Ashabani Abdelhakim, Abushofa Umaima, Abusrewill Suliman, et al. The prevalence of coeliac disease in Libyan children with type 1 diabetes mellitus. Diabetes/Metabolism Research and Reviews. 2003;19(1):69-75. Not sensitivity or specificity of an identified test. [pmid: 12592646].
Ashkenazi A, Berrebi A, Levi R, et al. Frequency of HLA-B8 in Israeli children with celiac disease. Israel Journal of Medical Sciences. 1979;15(10):826-828. Not sensitivity or specificity of an identified test. [pmid: 521261].
Asquith P. Adult coeliac disease and malignancy. Ir Med J. 1974;67(15):417-420. Not sensitivity or specificity of an identified test. [pmid: 4411887].
Asquith P, Johnson A G, Cooke W T. Scanning electron microscopy of normal and celiac jejunal mucosa. American Journal of Digestive Diseases. 1970;15(6):511-521. Unable to extract data. [pmid: 5445632].
Asselineau D, Bernard B A, Bailly C, et al. Retinoic acid improves epidermal morphogenesis. Developmental Biology. 1989;133(2):322-335. Not sensitivity or specificity of an identified test. [pmid: 2471653].
Assi A, Declich P, Iacobellis M, et al. Secretory meningioma, a rare meningioma subtype with characteristic glandular differentation: an histological and immunohistochemical study of 9 cases. Advances in Clinical Pathology - the Official Journal of Adriatic Society of Pathology. 1999;3(3):47-53. Not sensitivity or specificity of an identified test. [pmid: 10655573].
Astill T P, Ellis R J, Arif S, et al. Promiscuous binding of proinsulin peptides to Type 1 diabetes-permissive and -protective HLA class II molecules. Diabetologia. 2003;46(4):496-503. Not sensitivity or specificity of an identified test. [pmid: 12684749].
Atherton D J. Diagnosis and management of skin disorders caused by food allergy. Annals of Allergy. 1984;53(6 Pt 2):623-628. Not sensitivity or specificity of an identified test. [pmid: 6391291].
Atkinson K, Tokmakajian S, Watson W, et al. Evaluation of the endomysial antibody for celiac disease: operating properties and associated cost implications in clinical practice. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 1997;11(8):673-677. Improper control group. [pmid: 9459047].
Auld G C, Ritchie H, Robbie L A, et al. Thrombin upregulates tissue transglutaminase in endothelial cells: a potential role for tissue transglutaminase in stability of atherosclerotic plaque. Arteriosclerosis, Thrombosis, and Vascular Biology. 2001;21(10):1689-1694. Not sensitivity or specificity of an identified test. [pmid: 11597946].
Auricchio S. Gluten-sensitive enteropathy and infant nutrition. Journal of Pediatric Gastroenterology and Nutrition. 1983;2(Suppl 1):s304-s309. Not sensitivity or specificity of an identified test. [pmid: 6644476].
Auricchio S, Troncone R. Effects of small amounts of gluten in the diet of coeliac patients. Panminerva Medica. 1991;33(2):83-85. Not sensitivity or specificity of an identified test. [pmid: 1923558].
Auricchio S, Greco L, Troncone R. Gluten-sensitive enteropathy in childhood. Pediatric Clinics of North America. 1988;35(1):157-187. Not sensitivity or specificity of an identified test. [pmid: 3277130].
Auricchio S, Mazzacca G, Tosi R, et al. Coeliac disease as a familial condition: Identification of asymptomatic coeliac patients within family groups. Gastroenterol Int. 1988;1(1):25-31. Not sensitivity or specificity of an identified test.
Auricchio S, Troncone R, Maurano F. Coeliac disease in the year 2000. Italian Journal of Gastroenterology and Hepatology. 1999;31(8):773-780. Not sensitivity or specificity of an identified test. [pmid: 10730570].
Autuori F, Farrace M G, Oliverio S et al. “Tissue” transglutaminase and apoptosis. Advances in Biochemical Engineering/Biotechnology 1998;62129–136. Not sensitivity or specificity of an identified test
Avigad S, Manuel P, Bampoe V. Small-intestinal mucosal antibodies against antigens of non-pathogenic luminal or mucosal bacteria in young children with and without diarrhoea. Lancet. 1978;1(8074):1130-1132. Not sensitivity or specificity of an identified test. [pmid: 77420].
Avila-Portillo L M, Vargas-Alarcon G, Andrade F, et al. Linkage disequilibrium of HLA-DR3 and HLA-DR4 with HLA-B alleles in Mexican patients with rheumatoid arthritis. Clin Exp Rheumatol. 1994;12(5):497-502. Not sensitivity or specificity of an identified test. [pmid: 7842529].
Azurdia R M, Luzzi G A, Byren I, et al. Lichen sclerosus in adult men: A study of HLA associations and susceptibility to autoimmune disease. Br J Dermatol. 1999;140(1):79-83. Not sensitivity or specificity of an identified test. [pmid: 10215772].
Baden H P. Common transglutaminase substrates shared by hair, epidermis and nail and their function. Journal of Dermatological Science. 1994;7(Suppl):s20-s26. Not sensitivity or specificity of an identified test. [pmid: 7999673].
Baden H P, Kubilus J K, Phillips S B. Characterization of monoclonal antibodies generated to the cornified envelope of human cultured keratinocytes. Journal of Investigative Dermatology. 1987;89(5):454-459. Not sensitivity or specificity of an identified test. [pmid: 3668290].
Baden H P, Kubilus J, Phillips S B, et al. A new class of soluble basic protein precursors of the cornified envelope of mammalian epidermis. Biochimica Et Biophysica Acta. 1987;925(1):63-73. Not sensitivity or specificity of an identified test. [pmid: 2885033].
Badenhoop K, Donner H, Pani M, et al. Genetic susceptibility to type 1 diabetes: clinical and molecular heterogeneity of IDDM1 and IDDM12 in a german population. Experimental and Clinical Endocrinology & Diabetes - Official Journal, German Society of Endocrinology and German Diabetes Association. 1999;107(Suppl 3):s89-s92. Not sensitivity or specificity of an identified test. [pmid: 10522814].
Bagdi E, Diss T C, Munson P, et al. Mucosal intra-epithelial lymphocytes in enteropathy-associated T-cell lymphoma, ulcerative jejunitis, and refractory celiac disease constitute a neoplastic population. Blood. 1999;94(1):260-264. Not sensitivity or specificity of an identified test. [pmid: 10381521].
Bagnasco M, Montagna P, De Alessandri A, et al. IgA antiendomysium antibodies in human umbilical cord sections as a screening test in relatives of patients with celiac disease. Allergy. 1997;52(10):1017-1021. Improper control group. [pmid: 9360755].
Bahna S L, Tateno K, Heiner D C. Elevated IgD antibodies to wheat in celiac disease. Annals of Allergy. 1980;44(3):146-151. Not sensitivity or specificity of an identified test. [pmid: 7362093].
Bai J C. Malabsorption syndromes. Digestion. 1998;59(5):530-546. Not sensitivity or specificity of an identified test. [pmid: 9705537].
Bai J C, Sambuelli A, Sugai E, et al. Gluten challenge in patients with celiac disease: evaluation of alpha 1-antitrypsin clearance. American Journal of Gastroenterology. 1991;86(3):312-316. Not sensitivity or specificity of an identified test. [pmid: 1998313].
Bai J, Moran C, Martinez C, et al. Celiac sprue after surgery of the upper gastrointestinal tract. Report of 10 patients with special attention to diagnosis, clinical behavior, and follow-up. Journal of Clinical Gastroenterology. 1991;13(5):521-524. Not sensitivity or specificity of an identified test. [pmid: 1744387].
Bailey D S, Freedman A R, Price S C, et al. Early biochemical responses of the small intestine of coeliac patients to wheat gluten. Gut. 1989;30(1):78-85. Not sensitivity or specificity of an identified test. [pmid: 2563983]. [pmcid: 1378235].
Baker P G, Read A E. Oats and barley toxicity in coeliac patients. Postgrad Med J. 1976;52(607):264-268. Not sensitivity or specificity of an identified test. [pmid: 959100].
Baker P G, Barry R E, Read A E. Detection of continuing gluten ingestion in treated coeliac patients. British Medical Journal. 1975;1(5956):486-488. Not sensitivity or specificity of an identified test. [pmid: 1125587]. [pmcid: 1672594].
Baklien K, Brandtzaeg P, Fausa O. Immunoglobulins in jejunal mucosa and serum from patients with adult coeliac disease. Scandinavian Journal of Gastroenterology. 1977;12(2):149-159. Not sensitivity or specificity of an identified test. [pmid: 329404].
Baklien K, Fausa O, Brandtzaeg P. Malabsorption, villous atrophy, and excessive serum IgA in a patient with unusual intestinal immunocyte infiltration. Scandinavian Journal of Gastroenterology. 1977;12(4):421-432. Not sensitivity or specificity of an identified test. [pmid: 329404].
Balaji Madhuri, Shtauvere-Brameus A, Balaji V et al. Women diagnosed with gestational diabetes mellitus do not carry antibodies against minor islet cell antigens. Annals of the New York Academy of Sciences 2002;958281–284. Not sensitivity or specificity of an identified test
Balas A, Garcia-Novo M D, Martinez J, et al. Intestinal alphabeta T cells of symptomatic celiac disease patients show oligoclonal TCRBV repertoire but polyclonal rearrangement patterns. Human Immunology. 2000;61(3):247-254. Not sensitivity or specificity of an identified test. [pmid: 10689114].
Balas A, Santos S, Aviles M J, et al. Elongation of the cytoplasmic domain, due to a point deletion at exon 7, results in an HLA-C null allele, Cw*0409 N. Tissue Antigens. 2002;59(2):95-100. Not sensitivity or specificity of an identified test. [pmid: 12028535].
Balas A, Vicario J L, Zambrano A, et al. Absolute linkage of celiac disease and dermatitis herpetiformis to HLA-DQ. Tissue Antigens. 1997;50(1):52-56. Improper control group. [pmid: 9243756].
Baldas V, Tommasini A, Trevisiol C, et al. Development of a novel rapid non-invasive screening test for coeliac disease. Gut. 2000;47(5):628-631. Improper control group. [pmid: 11034577]. [pmcid: 1728098].
Balducci-Silano P L, Layrisse Z E. HLA-DP and susceptibility to insulin-dependent diabetes mellitus in an ethnically mixed population. Associations with other HLA-alleles. J Autoimmun. 1995;8(3):425-437. Not sensitivity or specificity of an identified test. [pmid: 7576003].
Baldwin J A. Schizophrenia and physical disease. Psychological Medicine. 1979;9(4):611-618. Not sensitivity or specificity of an identified test. [pmid: 390590].
Ball D J, Mayhew S, Vernon D I, et al. Decreased efficiency of trypsinization of cells following photodynamic therapy: evaluation of a role for tissue transglutaminase. Photochemistry and Photobiology. 2001;73(1):47-53. Not sensitivity or specificity of an identified test. [pmid: 11202365].
Balster Douglas A, O'Dorisio M, Sue Albers, et al. Suppression of tumorigenicity in neuroblastoma cells by upregulation of human vasoactive intestinal peptide receptor type 1. Regulatory Peptides. 2002;109(13):155-165. Not sensitivity or specificity of an identified test. [pmid: 12409228].
Bansal A S, Bruce J, Thomson A, et al. Serum levels of sCD23, interleukin-10 and interferon-gamma in patients with coeliac disease. J Gastroenterol Hepatol. 1997;12(910):685-689. Not sensitivity or specificity of an identified test. [pmid: 9407334].
Banwell J G, Gorbach S L, Mitra R, et al. Tropical sprue and malnutrition in West Bengal. II. Fluid and electrolyte transport in the small intestine. American Journal of Clinical Nutrition. 1970;23(12):1559-1568. Not sensitivity or specificity of an identified test. [pmid: 5481890].
Bao F, Yu L, Babu S, et al. One third of HLA DQ2 homozygous patients with type 1 diabetes express celiac disease-associated transglutaminase autoantibodies. Journal of Autoimmunity. 1999;13(1):143-148. Improper control group. [pmid: 10441179].
Bar H, Schlote W. Malignant melanoma in the CNS, subtyping and immunocytochemistry. Clinical Neuropathology. 1997;16(6):337-345. Not sensitivity or specificity of an identified test. [pmid: 9401802].
Barakat M H, Ali S M, Badawi A R, et al. Peroral endoscopic duodenal biopsy in infants and children. Acta Paediatrica Scandinavica. 1983;72(4):563-569. Not sensitivity or specificity of an identified test. [pmid: 6624433].
Barbato M, Miglietta M R, Viola F, et al. Impact of modification of diagnostic techniques and criteria on the presentation of celiac disease in the last 16 years. Observation in Rome. Minerva Pediatrica. 1996;48(9):359-363. Not sensitivity or specificity of an identified test. [pmid: 8968150].
Barbato M, Miglietta M R, Viola F, et al. Value of antigliadin antibodies (AGA) in latent coeliac disease (CD). Minerva Pediatrica. 2000;52(11):617-621. Test-specific exclusion. [pmid: 11204377].
Barbeau W E, Novascone M A, Elgert K D. Is celiac disease due to molecular mimicry between gliadin peptide-HLA class II molecule-T cell interactions and those of some unidentified superantigen?. Molecular Immunology. 1997;34(7):535-541. Not sensitivity or specificity of an identified test. [pmid: 9364219].
Barbera C, Fusco P, Ansaldi N, et al. HLA and antigluten antibodies in children with celiac disease. Diagn Clin Immunol. 1987;5(3):158-161. Not sensitivity or specificity of an identified test. [pmid: 3500808].
Bardare M, Villani R, Giunta A. Anti reticulin antibodies in malabsorption syndromes. Helv Paediatr Acta. 1974;29(3):203-211. Not sensitivity or specificity of an identified test. [pmid: 4136530].
Bardella M T, Fredella C, Prampolini L, et al. Gluten sensitivity in monozygous twins: A long-term follow-up of five pairs. American Journal of Gastroenterology. 2000;95(6):1503-1505. Not sensitivity or specificity of an identified test. [pmid: 10894587].
Bardella M T, Minoli G, Radaelli F, et al. Reevaluation of duodenal endoscopic markers in the diagnosis of celiac disease. Gastrointestinal Endoscopy. 2000;51(6):714-716. Not sensitivity or specificity of an identified test. [pmid: 10840306].
Bardella M T, Minoli G, Ravizza D, et al. Increased prevalence of celiac disease in patients with dyspepsia. Archives of Internal Medicine. 2000;160(10):1489-1491. Not sensitivity or specificity of an identified test. [pmid: 10826463].
Bardella M T, Molteni N, Cesana B, et al. IgA antigliadin antibodies, cellobiose/mannitol sugar test, and carotenemia in the diagnosis of and screening for celiac disease. American Journal of Gastroenterology. 1991;86(3):309-311. Improper control group. [pmid: 1900142].
Bardella M T, Molteni N, Quatrini M, et al. Clinical, biochemical and histological abnormalities in adult celiac patients on gluten-free diet. Gastroenterologie Clinique Et Biologique. 1985;9(11):787-789. Not sensitivity or specificity of an identified test. [pmid: 4085741].
Bardella M T, Quatrini M, Zuin M, et al. Screening patients with celiac disease for primary biliary cirrhosis and vice versa. American Journal of Gastroenterology. 1997;92(9):1524-1526. Not sensitivity or specificity of an identified test. [pmid: 9317077].
Bardella M T, Vecchi M, Conte D, et al. Chronic unexplained hypertransaminasemia may be caused by occult celiac disease. Hepatology (Baltimore, Md.). 1999;29(3):654-657. Not sensitivity or specificity of an identified test. [pmid: 10051464].
Bardos H, Juhasz A, Repassy G, et al. Fibrin deposition in squamous cell carcinomas of the larynx and hypopharynx. Thrombosis and Haemostasis. 1998;80(5):767-772. Not sensitivity or specificity of an identified test. [pmid: 9843169].
Barera G, Bianchi C, Calisti L, et al. Screening of diabetic children for coeliac disease with antigliadin antibodies and HLA typing. Archives of Disease in Childhood. 1991;66(4):491-494. Not sensitivity or specificity of an identified test. [pmid: 2031607].
Barera Graziano, Bonfanti Riccardo, Viscardi Matteo, et al. Occurrence of celiac disease after onset of type 1 diabetes: a 6-year prospective longitudinal study. Pediatrics. 2002;109(5):833-838. Not sensitivity or specificity of an identified test. [pmid: 11986443].
Barlow J M, Johnson C D, Stephens D H. Celiac disease: how common is jejunoileal fold pattern reversal found at small-bowel follow-through?. Ajr. American Journal of Roentgenology. 1996;166(3):575-577. Not sensitivity or specificity of an identified test. [pmid: 8623630].
Barna M, Pinter E. Anti-gliadin and anti-endomysium antibodies in children with celiac disease consuming a gluten free diet. Zeitschrift Fur Ernahrungswissenschaft. 1998;37(Suppl 1):103-105. Not sensitivity or specificity of an identified test. [pmid: 9558738].
Barnes G L. Duodenal biopsy in 75 New Zealand children. New Zealand Medical Journal. 1976;83(564):349-351. Not sensitivity or specificity of an identified test. [pmid: 1066562].
Barnes R M, Lewis-Jones M S. Isotype distribution and serial levels of antibodies reactive with dietary protein antigens in dermatitis herpetiformis. Journal of Clinical & Laboratory Immunology. 1989;30(2):87-91. Not sensitivity or specificity of an identified test. [pmid: 2641534].
Barnes R M, Harvey M M, Blears J, et al. IgG subclass of human serum antibodies reactive with dietary proteins. International Archives of Allergy and Applied Immunology. 1986;81(2):141-147. Not sensitivity or specificity of an identified test. [pmid: 3759257].
Barr G D, Grehan M J. Coeliac disease. Med J Aust. 1998;169(2):109-114. Not sensitivity or specificity of an identified test. [pmid: 9700349].
Barr G, Cameron D, King S, et al. Current status and management of coeliac disease. Med Today. 2003;4(6):30-39. Not sensitivity or specificity of an identified test.
Barresi G, Tuccari G, Magazzu G. Neutral mucins in coeliac disease. Basic and Applied Histochemistry. 1983;27(1):55-60. Not sensitivity or specificity of an identified test. [pmid: 6860257].
Barresi G, Tuccari G, Magazzu G, et al. Acid mucins in duodeno-jejunal biopsies from infants with coeliac disease. Applied Pathology. 1983;1(1):34-40. Not sensitivity or specificity of an identified test. [pmid: 6204661].
Barry E L, Mosher D F. Binding and degradation of blood coagulation factor XIII by cultured fibroblasts. Journal of Biological Chemistry. 1990;265(16):9302-9307. Not sensitivity or specificity of an identified test. [pmid: 1971626].
Barry R E. ‘Coeliac disease and malignancy’. Tgastro-Ent. 1973;16(1):23-34. Not sensitivity or specificity of an identified test.
Barry R E, Read A E. Coeliac disease and malignancy. Quarterly Journal of Medicine. 1973;42(168):665-675. Not sensitivity or specificity of an identified test. [pmid: 4802432].
Barshack I, Goldberg I, Chowers Y, et al. Immunohistochemical analysis of candidate gene product expression in the duodenal epithelium of children with coeliac sprue. Journal of Clinical Pathology. 2001;54(9):684-688. Not sensitivity or specificity of an identified test. [pmid: 11533074]. [pmcid: 1731505].
Barsoum R, Nabil M, Saady G, et al. Immunoglobulin-A and the pathogenesis of schistosomal glomerulopathy. Kidney International. 1996;50(3):920-928. Not sensitivity or specificity of an identified test. [pmid: 8872967].
Barta L, Kosnai I, Molnar M, et al. Simultaneous occurrence of diabetes mellitus and coeliac disease. Acta Paediatrica Hungarica. 1985;26(4):303-306. Not sensitivity or specificity of an identified test. [pmid: 3879451].
Barta Z, Csipo tilde, Szabo G G, et al. Seroreactvity against Saccharomyces cerevisiae in patients with Crohn's disease and celiac disease. World J Gastroenterol. 2003;9(10):2308-2312. Not sensitivity or specificity of an identified test. [pmid: 14562398].
Bartholomeusz R C, Labrooy J T, Davidson G P, et al. Polymeric IgA antibody to gliadin in the serum of patients with coeliac disease. Journal of Gastroenterology and Hepatology. 1990;5(6):675-681. Not sensitivity or specificity of an identified test. [pmid: 2129839].
Batar P, Dale G L. Simultaneous engagement of thrombin and Fc gamma RIIA receptors results in platelets expressing high levels of procoagulant proteins. Journal of Laboratory and Clinical Medicine. 2001;138(6):393-402. Not sensitivity or specificity of an identified test. [pmid: 11753286].
Bateson M C, Hopwood D, MacGillivray J B. Jejunal morphology in multiple sclerosis. Lancet. 1979;1(8126):1108-1110. Not sensitivity or specificity of an identified test. [pmid: 86833].
Batt R M, Carter M W, McLean L. Morphological and biochemical studies of a naturally occurring enteropathy in the Irish setter dog: a comparison with coeliac disease in man. Research in Veterinary Science. 1984;37(3):339-346. Not sensitivity or specificity of an identified test. [pmid: 6522828].
Battelli M G, Musiani S, Tazzari P L, et al. Oxidative stress to human lymphocytes by xanthine oxidoreductase activity. Free Radical Research. 2001;35(6):665-679. Not sensitivity or specificity of an identified test. [pmid: 11811520].
Baur X, Rihs H-P, Altmeyer P, et al. Systemic sclerosis in German uranium miners under special consideration of autoantibody subsets and HLA class II alleles. Respiration. 1996;63(6):368-375. Not sensitivity or specificity of an identified test. [pmid: 8933656].
Bayless T M, Wheby M S, Swanson V L. Tropical sprue in Puerto Rico. American Journal of Clinical Nutrition. 1968;21(9):1030-1041. Not sensitivity or specificity of an identified test. [pmid: 5675842].
Bazinet P, Marin G A. Malabsorption in systemic lupus erythematosus. American Journal of Digestive Diseases. 1971;16(5):460-466. Not sensitivity or specificity of an identified test. [pmid: 5578520].
Bazzigaluppi E, Lampasona V, Barera G, et al. Comparison of tissue transglutaminase-specific antibody assays with established antibody measurements for coeliac disease. Journal of Autoimmunity. 1999;12(1):51-56. Improper control group. [pmid: 10028022].
Beard R L, Chandraratna R A, Colon D F, et al. Synthesis and structure-activity relationships of stilbene retinoid analogs substituted with heteroaromatic carboxylic acids. Journal of Medicinal Chemistry. 1995;38(15):2820-2829. Not sensitivity or specificity of an identified test. [pmid: 7636843].
Beaumont D M, Mian M S. Coeliac disease in old age: ‘A catch in the rye’. Age Ageing. 1998;27(4):535-538. Not sensitivity or specificity of an identified test. [pmid: 9884015].
Beck I T, Da Costa L R, Beck M. Sugar absorption by small bowel biopsy samples from patients with primary lactase deficiency and with adult celiac disease. American Journal of Digestive Diseases. 1976;21(11):946-952. Not sensitivity or specificity of an identified test. [pmid: 984015].
Beckett C G, Ciclitira P J. Celiac disase. Curr Opin Gastroenterol. 1997;13(2):107-111. Not sensitivity or specificity of an identified test.
Beckett C G, Dell'Olio D, Ellis H J, et al. The detection and localization of inducible nitric oxide synthase production in the small intestine of patients with coeliac disease. European Journal of Gastroenterology & Hepatology. 1998;10(8):641-647. Not sensitivity or specificity of an identified test. [pmid: 9744691].
Beckett C G, Dell'Olio D, Kontakou M, et al. Analysis of interleukin-4 and interleukin-10 and their association with the lymphocytic infiltrate in the small intestine of patients with coeliac disease. Gut. 1996;39(96):818-823. Not sensitivity or specificity of an identified test. [pmid: 9038663]. [pmcid: 1383453].
Beckett C G, Dell'Olio D, Schidrawi R G, et al. Gluten-induced nitric oxide and pro-inflammatory cytokine release by cultured coeliac small intestinal biopsies. European Journal of Gastroenterology & Hepatology. 1999;11(5):529-535. Not sensitivity or specificity of an identified test. [pmid: 10755257].
Bedrossian C W, Bonsib S, Moran C. Differential diagnosis between mesothelioma and adenocarcinoma: a multimodal approach based on ultrastructure and immunocytochemistry. Seminars in Diagnostic Pathology. 1992;9(2):124-140. Not sensitivity or specificity of an identified test. [pmid: 1609155].
Behr W, Barnert J. Adult celiac disease and primary biliary cirrhosis. American Journal of Gastroenterology. 1986;81(9):796-799. Not sensitivity or specificity of an identified test. [pmid: 3489408].
Behrendt N, Ronne E, Dano K. A novel, specific pro-urokinase complex on monocyte-like cells, detected by transglutaminase-catalyzed cross-linking. Febs Letters. 1993;336(3):394-396. Not sensitivity or specificity of an identified test. [pmid: 7904248].
Belkin A M, Akimov S S, Zaritskaya L S, et al. Matrix-dependent proteolysis of surface transglutaminase by membrane-type metalloproteinase regulates cancer cell adhesion and locomotion. Journal of Biological Chemistry. 2001;276(21):18415-18422. Not sensitivity or specificity of an identified test. [pmid: 11278623].
Bell J I. The major histocompatibility complex and disease. Current Opinion in Immunology. 1989;2(1):114-116. Not sensitivity or specificity of an identified test. [pmid: 2692618].
Bell J, Rassenti L, Smoot S, et al. HLA-DQ beta-chain polymorphism linked to myasthenia gravis. Lancet. 1986;1(8489):1058-1060. Not sensitivity or specificity of an identified test. [pmid: 2871336].
Bell S, Green P H R, Kagnoff M F. American gastroenterological association medical position statement: Celiac sprue. Gastroenterology. 2001;120(6):1522-1525. Not sensitivity or specificity of an identified test. [pmid: 11313323].
Bellanti J A, Zeligs B J, Malka-Rais J, et al. Abnormalities of ThSUB1 function in non-IgE food allergy, celiac disease, and ileal lymphonodular hyperplasia: A new relationship?. Annals of Allergy, Asthma & Immunology - Official Publication of the American College of Allergy, Asthma, & Immunology. 2003;90(Suppl):84-89. Not sensitivity or specificity of an identified test. [pmid: 12839120].
Belloni Cesare, Avanzini Maria A, De Silvestri, et al. No evidence of autoimmunity in 6-year-old children immunized at birth with recombinant hepatitis B vaccine. Pediatrics. 2002;110(1 Pt1):E4. Not sensitivity or specificity of an identified test. [pmid: 12093985].
Beltrami C A, Barbatelli G, Criante P, et al. An immunohistochemical study in thyroid cancer. Applied Pathology. 1987;5(4):229-245. Not sensitivity or specificity of an identified test. [pmid: 2446641].
Bender S W, Posselt H G, Staps M, et al. Biochemical quantification of crypt hyperplastic villous atrophy by aldolase activity assay. Journal of Pediatric Gastroenterology and Nutrition. 1984;3(4):506-509. Not sensitivity or specificity of an identified test. [pmid: 6481561].
Bendixen E, Harpel P C, Sottrup-Jensen L. Location of the major epsilon-(gamma-glutamyl)lysyl cross-linking site in transglutaminase-modified human plasminogen. Journal of Biological Chemistry. 1995;270(30):17929-17933. Not sensitivity or specificity of an identified test. [pmid: 7629099].
Bendl B J, Williams P B. Histopathological changes in the jejunal mucosa in dermatitis herpetiformis. Canadian Medical Association Journal. 1968;98(12):575-577. Not sensitivity or specificity of an identified test. [pmid: 5641504]. [pmcid: 1923968].
Beninati S, Senger D R, Cordella-Miele E, et al. Osteopontin: Its transglutaminase-catalyzed posttranslational modifications and cross-linking to fibronectin. J Biochem. 1994;115(4):675-682. Not sensitivity or specificity of an identified test. [pmid: 7916341].
Bennett R A, Whitelock T, Kelley J L. Eosinophilic gastroenteritis, gluten enteropathy, and dermatitis herpetiformis. American Journal of Digestive Diseases. 1974;19(12):1154-1161. Not sensitivity or specificity of an identified test. [pmid: 4440670].
Benzinger T L, Gregory D M, Burkoth T S, et al. Propagating structure of Alzheimer's beta-amyloid(10–35) is parallel beta-sheet with residues in exact register. Proceedings of the National Academy of Sciences of the United States of America. 1998;95(23):13407-13412. Not sensitivity or specificity of an identified test. [pmid: 9811813]. [pmcid: 24832].
Berdoz J, Tiercy J-M, Rollini P, et al. Remarkable sequence conservation of the HLA-DQB2 locus (DXbeta) within the highly polymorphic DQ subregion of the human MHC. Immunogenetics. 1989;29(4):241-248. Not sensitivity or specificity of an identified test. [pmid: 2564844].
Berg A, Eriksson M, Barany F. Hydrogen concentration in expired air analyzed with a new hydrogen sensor, plasma glucose rise, and symptoms of lactose intolerance after oral administration of 100 gram lactose. Scandinavian Journal of Gastroenterology. 1985;20(7):814-822. Not sensitivity or specificity of an identified test. [pmid: 4048833].
Berg L, Ronnelid J, Sanjeevi C B, et al. Interferon-gamma production in response to in vitro stimulation with collagen type II in rheumatoid arthritis is associated with HLA-DRB1*0401 and HLA-DQ8. Arthritis Res. 2000;2(1):75-84. Not sensitivity or specificity of an identified test. [pmid: 11219392]. [pmcid: 17806].
Berg N O, Lindberg T. Incidence of coeliac disease and transient gluten intolerance in children in a Swedish urban community. Acta Paediatr Scand. 1979;68(3):397-400. Not sensitivity or specificity of an identified test. [pmid: 575016].
Berg N O, Dahlqvist A, Lindberg T, et al. Correlation between morphological alterations and enzyme activities in the mucosa of the small intestine. Scandinavian Journal of Gastroenterology. 1973;8(8):703-712. Not sensitivity or specificity of an identified test. [pmid: 4771109].
Bergamini A, Capozzi M, Piacentini M. Macrophage-colony stimulating factor (M-CSF) stimulation induces cell death in HIV-infected human monocytes. Immunology Letters. 1994;42(12):35-40. Not sensitivity or specificity of an identified test. [pmid: 7829127].
Bergamini C M, Signorini M. Studies on tissue transglutaminases: interaction of erythrocyte type-2 transglutaminase with GTP. Biochemical Journal. 1993;291(Pt 1):37-39. Not sensitivity or specificity of an identified test. [pmid: 8097088]. [pmcid: 1132477].
Bergamini C M, Signorini M, Barbato R, et al. Transglutaminase-catalyzed polymerization of troponin in vitro. Biochemical and Biophysical Research Communications. 1995;206(1):201-206. Not sensitivity or specificity of an identified test. [pmid: 7818521].
Bernard B A, Asselineau D, Schaffar-Deshayes L, et al. Abnormal sequence of expression of differentiation markers in psoriatic epidermis: inversion of two steps in the differentiation program?. Journal of Investigative Dermatology. 1988;90(6):801-805. Not sensitivity or specificity of an identified test. [pmid: 3286778].
Bernard B A, Reano A, Darmon Y M, et al. Precocious appearance of involucrin and epidermal transglutaminase during differentiation of psoriatic skin. British Journal of Dermatology. 1986;114(3):279-283. Not sensitivity or specificity of an identified test. [pmid: 2869777].
Bernardini S, Melino G, Cortese C, et al. Modulation of glutathione transferase P1-1 activity by retinoic acid in neuroblastoma cells. Journal of Cellular Biochemistry. 1999;75(3):375-381. Not sensitivity or specificity of an identified test. [pmid: 10536361].
Bernassola F, Rossi A, Melino G. Regulation of transglutaminases by nitric oxide. Annals of the New York Academy of Sciences 1999;88783–91. Not sensitivity or specificity of an identified test
Bernassola F, Scheuerpflug C, Herr I, et al. Induction of apoptosis by IFNgamma in human neuroblastoma cell lines through the CD95/CD95L autocrine circuit. Cell Death and Differentiation. 1999;6(7):652-660. Not sensitivity or specificity of an identified test. [pmid: 10453076].
Bernstein Charles N, Leslie William D, Leboff Meryl S. AGA technical review on osteoporosis in gastrointestinal diseases. Gastroenterology. 2003;124(3):795-841. Not sensitivity or specificity of an identified test. [pmid: 12612917].
Berrill W T, van Rood J J. HLA-DW6 and avian hypersensitivity. Lancet. 1977;2(8031):248-249. Not sensitivity or specificity of an identified test. [pmid: 69855].
Berrill W T, Eade O E, Fitzpatrick P F. Bird Fancier's lung and jejunal villous atrophy. Lancet. 1975;2(7943):1006-1008. Not sensitivity or specificity of an identified test. [pmid: 53495].
Berrutti L, Silverman J S. Cardiac myxoma is rich in factor XIIIa positive dendrophages: immunohistochemical study of four cases. Histopathology. 1996;28(6):529-535. Not sensitivity or specificity of an identified test. [pmid: 8803596].
Berstad A E, Brandtzaeg P. Expression of cell membrane complement regulatory glycoproteins along the normal and diseased human gastrointestinal tract. Gut. 1998;42(4):522-529. Not sensitivity or specificity of an identified test. [pmid: 9616315]. [pmcid: 1727075].
Bertele R M, Burgin-Wolff A, Berger R, et al. The fluorescent immunosorbent test for IgG gliadin antibodies and the leucocyte migration inhibition test in coeliac disease; comparison of diagnostic value. European Journal of Pediatrics. 1985;144(1):58-62. Not sensitivity or specificity of an identified test. [pmid: 3926501].
Berthon P, Pancino G, de Cremoux P, et al. Characterization of normal breast epithelial cells in primary cultures: differentiation and growth factor receptors studies. In Vitro Cellular & Developmental Biology - Journal of the Tissue Culture Association. 1992;28a(1112):716-724. Not sensitivity or specificity of an identified test. [pmid: 1282913].
Berti I, Trevisiol C, Tommasini A, et al. Usefulness of screening program for celiac disease in autoimmune thyroiditis. Digestive Diseases and Sciences. 2000;45(2):403-406. Not sensitivity or specificity of an identified test. [pmid: 10711459].
Berzina L, Ludvigsson J, Sadauskaite-Kuehne V et al. DR3 is associated with type 1 diabetes and blood group ABO incompatibility. Annals of the New York Academy of Sciences 2002;958345–348. Not sensitivity or specificity of an identified test
Berzina L, Shtauvere-Brameus A, Ludvigsson J et al. Newborn screening for high-risk human leukocyte antigen markers associated with insulin-dependent diabetes mellitus: the ABIS study. Annals of the New York Academy of Sciences 2002;958312–316. Not sensitivity or specificity of an identified test
Besterman H S, Cook G C, Sarson D L. Gut hormones in tropical malabsorption. Br Med J. 1979;2(6200):1252-1255. Not sensitivity or specificity of an identified test. [pmid: 519400]. [pmcid: 1596913].
Bettinotti M P, Hartung K, Deicher H, et al. Polymorphism of the tumor necrosis factor beta gene in systemic lupus erythematosus: TNFB-MHC haplotypes. Immunogenetics. 1993;37(6):449-454. Not sensitivity or specificity of an identified test. [pmid: 8463000].
Betuel H, Gebuhrer L, Descos L, et al. Adult celiac disease associated with HLA-DRw3 and -DRw7. Tissue Antigens. 1980;15(3):231-238. Not sensitivity or specificity of an identified test. [pmid: 6936866].
Beutner E H, Chorzelski T P, Kumar V, et al. Sensitivity and specificity of IgA-class antiendomysial antibodies for dermatitis herpetiformis and findings relevant to their pathogenic significance. Journal of the American Academy of Dermatology. 1986;15(3):464-473. Not sensitivity or specificity of an identified test. [pmid: 3093545].
Beutner E H, Kumar V, Chorzelski T P, et al. IgG endomysial antibodies in IgA-deficient patient with coeliac disease. Lancet. 1989;1(8649):1261-1262. Not sensitivity or specificity of an identified test. [pmid: 2566799].
Bevan S, Popat S, Houlston R S. Relative power of linkage and transmission disequilibrium test strategies to detect non-HLA linked coeliac disease susceptibility genes. Gut. 1999;45(5):668-671. Not sensitivity or specificity of an identified test. [pmid: 10517901]. [pmcid: 1727705].
Bevan S, Popat S, Braegger C P, et al. Contribution of the MHC region to the familial risk of coeliac disease. Journal of Medical Genetics. 1999;36(9):687-690. Not sensitivity or specificity of an identified test. [pmid: 10507725].
Bhatnagar S, Bhan M K. Serological diagnosis of celiac disease. Indian Journal of Pediatrics. 1999;66(1 Suppl):S26-S31. Review article. [pmid: 11132465].
Biagi F, Corazza G R. Tissue transglutaminase antibodies: is sensitivity more important than specificity?. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2001;33(5):401-402. Review article. [pmid: 11785714].
Biagi F, Corazza G R. Contribution of molecular genetics to gastroenterology: the case of coeliac disease. Italian Journal of Gastroenterology and Hepatology. 1999;31(3):202-204. Not sensitivity or specificity of an identified test. [pmid: 10379480].
Biagi F, Corazza G R. Gene and gliadin/gut and kidney. American Journal of Gastroenterology. 2002;97(10):2486-2488. Not sensitivity or specificity of an identified test. [pmid: 12385427].
Biagi F, Corazza G R. Clinical features of coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(3):225-228. Not sensitivity or specificity of an identified test. [pmid: 12408460].
Biagi F, Corazza G R. Defining gluten refractory enteropathy. European Journal of Gastroenterology & Hepatology. 2001;13(5):561-565. Not sensitivity or specificity of an identified test. [pmid: 11396537].
Biagi F, Bassi E, Ardigo M, et al. In patients with dermatitis herpetiformis distribution of transglutaminase in cutaneous tissue does not differ from controls. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2003;35(1):41-45. Not sensitivity or specificity of an identified test. [pmid: 12725607].
Biagi F, Ellis H J, Parnell N D, et al. A non-toxic analogue of a coeliac-activating gliadin peptide: a basis for immunomodulation?. Alimentary Pharmacology & Therapeutics. 1999;13(7):945-950. Not sensitivity or specificity of an identified test. [pmid: 10383530].
Biagi F, Ellis H J, Yiannakou J Y, et al. Tissue transglutaminase antibodies in celiac disease. American Journal of Gastroenterology. 1999;94(8):2187-2192. Improper control group. [pmid: 10445548].
Biagi F, Lorenzini P, Corazza G R. Literature review on the clinical relationship between ulcerative jejunoileitis, coeliac disease, and enteropathy-associated T-cell lymphoma. Scandinavian Journal of Gastroenterology. 2000;35(8):785-790. Not sensitivity or specificity of an identified test. [pmid: 10994614].
Biagi F, Parnell N D, Ellis H J, et al. Endomysial antibody production is not related to histological damage after in vitro gluten challenge. European Journal of Gastroenterology & Hepatology. 2000;12(1):57-60. Not sensitivity or specificity of an identified test. [pmid: 10656211].
Biagi F, Parnell N D, Thomas P D, et al. A new model for the pathogenesis of celiac disease. Gastroenterology. 1999;116(5):1277-1278. Not sensitivity or specificity of an identified test. [pmid: 10220531].
Biagi F, Zimmer K P, Thomas P D, et al. Is gliadin mispresented to the immune system in coeliac disease? A hypothesis. Qjm - Monthly Journal of the Association of Physicians. 1999;92(2):119-122. Not sensitivity or specificity of an identified test. [pmid: 10209663].
Bianchi L, Farrace M G, Nini G, et al. Abnormal Bcl-2 and “tissue” transglutaminase expression in psoriatic skin. Journal of Investigative Dermatology. 1994;103(6):829-833. Not sensitivity or specificity of an identified test. [pmid: 7798623].
Bieda K, Pani M A, van der, et al. A retroviral long terminal repeat adjacent to the HLA DQB1 gene (DQ-LTR13) modifies Type I diabetes susceptibility on high risk DQ haplotypes. Diabetologia. 2002;45(3):443-447. Not sensitivity or specificity of an identified test. [pmid: 11914751].
Biempica L, Toccalino H, O'Donnell J C. Cytochemical and ultrastructural studies of the intestinal mucosa of children with celiac disease. American Journal of Pathology. 1968;52(4):795-823. Unable to extract data. [pmid: 4296118]. [pmcid: 2013373].
Bilbao J R, Martin-Pagola A, Calvo B, et al. Contribution of MIC-A polymorphism to type 1 diabetes mellitus in Basques. Ann New York Acad Sci. 2002;958(-):321-324. Not sensitivity or specificity of an identified test. [pmid: 12021133].
Bilbao J R, Martin-Pagola A, Vitoria J C, et al. HLA-DRB1 and MHC class 1 chain-related A haplotypes in Basque families with celiac disease. Tissue Antigens. 2002;60(1):71-76. Not sensitivity or specificity of an identified test. [pmid: 12366785].
Bilbao J, Ramon Vitoria, Juan C, et al. Immunoglobulin G autoantibodies against tissue-transglutaminase. A sensitive, cost-effective assay for the screening of celiac disease. Autoimmunity. 2002;35(4):255-259. Improper control group. [pmid: 12482193].
Binder G, Ranke M B, Martin D D. Auxology Is a Valuable Instrument for the Clinical Diagnosis of SHOX Haploinsufficiency in School-Age Children with Unexplained Short Stature. J Clin Endocrinol Metab. 2003;88(10):4891-4896. Not sensitivity or specificity of an identified test. [pmid: 14602760].
Binder H J. Cediac sprue--“unmasking” after vagotomy and hiatal-hernia repair. New England Journal of Medicine. 1970;283(10):520-521. Not sensitivity or specificity of an identified test. [pmid: 5434137].
Bini E J. Helicobacter pylori and iron deficiency anemia: Guilty as charged?. Am J Med. 2001;111(6):495-497. Not sensitivity or specificity of an identified test. [pmid: 11690578].
Birckbichler P J, Patterson M K. Transglutaminase and epsilon-(gamma-glutamyl) lysine isopeptide bonds in eukaryotic cells. Progress in Clinical and Biological Research 1980;41845–855. Not sensitivity or specificity of an identified test
Birckbichler P J, Bonner R B, Hurst R E, et al. Loss of tissue transglutaminase as a biomarker for prostate adenocarcinoma. Cancer. 2000;89(2):412-423. Not sensitivity or specificity of an identified test. [pmid: 10918174].
Birckbichler P J, Orr G R, Patterson M K, et al. Enhanced transglutaminase activity in transformed human lung fibroblast cells after exposure to sodium butyrate. Biochimica Et Biophysica Acta. 1983;763(1):27-34. Not sensitivity or specificity of an identified test. [pmid: 6135451].
Birckbichler P J, Upchurch H F, Patterson M K et al. Detection of cellular transglutaminase using monoclonal antibody. Fed Proc 1984;43(6):No 2082Not sensitivity or specificity of an identified test
Birckbichler P J, Upchurch H F, Patterson M K, et al. A monoclonal antibody to cellular transglutaminase. Hybridoma. 1985;4(2):179-186. Not sensitivity or specificity of an identified test. [pmid: 2861155].
Birinci A, Birinci H, Abidinoglu R, et al. Diabetic retinopathy and HLA antigens in type 2 diabetes mellitus. Eur J Ophthalmol. 2002;12(2):89-93. Not sensitivity or specificity of an identified test. [pmid: 12022291].
Birol Ahu, Anadolu Rana, Yavuzer Tutkak, et al. HLA-class 1 and class 2 antigens in Turkish patients with pemphigus. International Journal of Dermatology. 2002;41(2):79-83. Not sensitivity or specificity of an identified test. [pmid: 11982641].
Bischoff S C, Mayer J, Wedemeyer J, et al. Colonoscopic allergen provocation (COLAP): a new diagnostic approach for gastrointestinal food allergy. Gut. 1997;40(6):745-753. Not sensitivity or specificity of an identified test. [pmid: 9245928]. [pmcid: 1027199].
Bishara A, Brautbar C, Nagler A. HLA and graft-versus-host disease: A population-based study of HLA phenotypes of Jewish and Arabic bone marrow transplanted patients in Israel. Leuk Res. 1997;21(2):111-118. Not sensitivity or specificity of an identified test. [pmid: 9112427].
Bittinger M, Barnert J, Schmidbaur W, et al. D-xylose hydrogen-breath test as a noninvasive screening test for Coeliac disease. What is the optimum xylose dose?. Rom J Gastroenterol. 1997;6(4):235-238. Not sensitivity or specificity of an identified test.
Bittolo M, Not T, Perticarari S, et al. A dot immunobinding assay to detect anti-alpha-gliadin antibodies in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1990;11(3):337-341. Not sensitivity or specificity of an identified test. [pmid: 2246715].
Bizzaro N, Villalta D, Tonutti E, et al. Association of celiac disease with connective tissue diseases and autoimmune diseases of the digestive tract. Autoimmun Rev. 2003;2(6):358-363. Not sensitivity or specificity of an identified test. [pmid: 14550877].
Bjarnason I, Batt R, Catt S, et al. Evaluation of differential disaccharide excretion in urine for non-invasive investigation of altered intestinal disaccharidase activity caused by alpha-glucosidase inhibition, primary hypolactasia, and coeliac disease. Gut. 1996;39(3):374-381. Not sensitivity or specificity of an identified test. [pmid: 8949640]. [pmcid: 1383342].
Bjarnason I, Goolamali S K, Levi A J, et al. Intestinal permeability in patients with atopic eczema. British Journal of Dermatology. 1985;112(3):291-297. Not sensitivity or specificity of an identified test. [pmid: 3919753].
Bjarnason I, Marsh M N, Price A, et al. Intestinal permeability in patients with coeliac disease and dermatitis herpetiformis. Gut. 1985;26(11):1214-1219. Not sensitivity or specificity of an identified test. [pmid: 3934051]. [pmcid: 1432901].
Bjarnason I, Peters T J, Veall N. A persistent defect in intestinal permeability in coeliac disease demonstrated by a 51Cr-labelled EDTA absorption test. Lancet. 1983;1(8320):323-325. Not sensitivity or specificity of an identified test. [pmid: 6134083].
Bjerrum O J, Heegaard N H H. Has immunoblotting replaced electroimmunoprecipitation? Examples from the analysis of autoantigens and transglutaminase-induced polymers of the human erythrocyte membrane. J Chromatogr. 1989;470(2):351-367. Not sensitivity or specificity of an identified test. [pmid: 2475516].
Bjorksten F, Backman A, Jarvinen K A, et al. Immunoglobulin E specific to wheat and rye flour proteins. Clinical Allergy. 1977;7(5):473-483. Not sensitivity or specificity of an identified test. [pmid: 589781].
Bjorneklett A, Fausa O, Refsum S B. Jejunal villous atrophy and granulomatous inflammation responding to a gluten free diet. Gut. 1977;18(10):814-816. Not sensitivity or specificity of an identified test. [pmid: 590839]. [pmcid: 1411681].
Black Kay E, Murray Joseph A, David Chella S. HLA-DQ determines the response to exogenous wheat proteins: a model of gluten sensitivity in transgenic knockout mice. Journal of Immunology (Baltimore, Md.- 1950). 2002;169(10):5595-5600. Not sensitivity or specificity of an identified test. [pmid: 12421937].
Blackwell P J, Hill P G, Holmes G K T. Autoantibodies to human tissue transglutaminase: superior predictors of coeliac disease. Scandinavian Journal of Gastroenterology. 2002;37(11):1282-1285. Improper control group. [pmid: 12465726].
Blanco A, Alonso M, Cilleruelo M L, et al. Increased serum beta2-microglobulin levels in active celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1985;4(3):388-392. Not sensitivity or specificity of an identified test. [pmid: 2410583].
Blanco A, Arranz E, Alonso M, et al. IgA1, IgA2 or secretory piece containing antigliadin antibodies in the sera of coeliac patients. Allergologia Et Immunopathologia. 1989;17(2):77-80. Not sensitivity or specificity of an identified test. [pmid: 2773754].
Blanco A, Garrote J A, Alonso M et al. Soluble CD4 antigen is increased in active coeliac disease. Advances in Experimental Medicine and Biology 1995;371b1355–1358. Not sensitivity or specificity of an identified test
Blanco A, Garrote J A, Arranz E, et al. Increased serum IL-2R levels in coeliac disease are related to CD4 but not CD8 antigens. Journal of Pediatric Gastroenterology and Nutrition. 1992;15(4):413-417. Not sensitivity or specificity of an identified test. [pmid: 1469522].
Blazer S, Naveh Y, Berant M, et al. Serum IgG antibodies to gliadin in children with celiac disease as measured by an immunofluorescence method. Journal of Pediatric Gastroenterology and Nutrition. 1984;3(2):205-209. Serology <1990. [pmid: 6368789].
Bloch R, Menge H, Lingelbach B, et al. The relationship between structure and function of small intestine in patients with a sprue syndrome and in healthy controls. Klinische Wochenschrift. 1973;51(23):1151-1158. Not sensitivity or specificity of an identified test. [pmid: 4272971].
Blomme B, Gerlo E, Hauser B, et al. Disaccharidase activities in Belgian children: Reference intervals and comparison with non-Belgian Caucasian children. Acta Paediatr Int J Paediatr. 2003;92(7):806-810. Not sensitivity or specificity of an identified test.
Boberg K M, Spurkland A, Rocca G, et al. The HLA-DR3,DQ2 heterozygous genotype is associated with an accelerated progression of primary sclerosing cholangitis. Scandinavian Journal of Gastroenterology. 2001;36(8):886-890. Not sensitivity or specificity of an identified test. [pmid: 11495087].
Bock S A. Food sensitivity: a critical review and practical approach. American Journal of Diseases of Children (1960). 1980;134(10):973-982. Not sensitivity or specificity of an identified test. [pmid: 6999892].
Boda M, Nemeth I, Boda D. The caffeine metabolic ratio as an index of xanthine oxidase activity in clinically active and silent celiac patients. Journal of Pediatric Gastroenterology and Nutrition. 1999;29(5):546-550. Not sensitivity or specificity of an identified test. [pmid: 10554121].
Bodanszky H, Horvath K, Horn G. The D-xylose test in coeliac disease. Acta Paediatrica Hungarica. 1983;24(1):17-22. Not sensitivity or specificity of an identified test. [pmid: 6613572].
Bodanszky H, Horvath K, Bata A, et al. Hydrogen breath test in small intestinal malabsorption. Acta Paediatrica Hungarica. 1987;28(1):45-49. Not sensitivity or specificity of an identified test. [pmid: 3620196].
Bode S, Gudmand-Hoyer E. Symptoms and haematologic features in consecutive adult coeliac patients. Scandinavian Journal of Gastroenterology. 1996;31(1):54-60. Not sensitivity or specificity of an identified test. [pmid: 8819220].
Bode S, Gudmand-Hoyer E. Incidence and clinical significance of lactose malabsorption in adult coeliac disease. Scandinavian Journal of Gastroenterology. 1988;23(4):484-488. Not sensitivity or specificity of an identified test. [pmid: 3132738].
Bodmer W F. The HLA system and disease. The Oliver Sharpey Lecture 1979. Journal of the Royal College of Physicians of London. 1980;14(1):43-50. Not sensitivity or specificity of an identified test. [pmid: 6777490].
Boehm Jason E, Singh Ugra, Combs Carolyn, et al. Tissue transglutaminase protects against apoptosis by modifying the tumor suppressor protein p110 Rb. Journal of Biological Chemistry. 2002;277(23):20127-20130. Not sensitivity or specificity of an identified test. [pmid: 11956182].
Boersma E R. Serum immunoglobulins IgG, IgM, and IgA in maternal cord blood pairs from infants of normal and low birthweights in Tanzania. Archives of Disease in Childhood. 1981;56(1):31-35. Not sensitivity or specificity of an identified test. [pmid: 7469449].
Bognetti E, Riva M C, Bonfanti R, et al. Growth changes in children and adolescents with short-term diabetes. Diabetes Care. 1998;21(8):1226-1229. Not sensitivity or specificity of an identified test. [pmid: 9702424].
Bolme P, Eriksson M, Stintzing G. The gastrointestinal absorption of penicillin V in children with suspected coeliac disease. Acta Paediatrica Scandinavica. 1977;66(5):573-578. Not sensitivity or specificity of an identified test. [pmid: 409098].
Bolognesi E, Karell K, Percopo S, et al. Additional factor in some HLA DR3/DQ2 haplotypes confers a fourfold increased genetic risk of celiac disease. Tissue Antigens. 2003;61(4):308-316. Not sensitivity or specificity of an identified test. [pmid: 12753669].
Bolsover W J, Hall M A, Vaughan R W, et al. A family study confirms that the HLA-DP associations with celiac disease are the result of an extended HLA-DR3 haplotype. Human Immunology. 1991;31(2):100-108. Not sensitivity or specificity of an identified test. [pmid: 1676703].
Bonamico M, Ballati G, Mariani P, et al. Screening for coeliac disease: the meaning of low titers of anti-gliadin antibodies (AGA) in non-coeliac children. European Journal of Epidemiology. 1997;13(1):55-59. Not sensitivity or specificity of an identified test. [pmid: 9062780].
Bonamico M, Bottaro G, Pasquino A M, et al. Celiac disease and turner syndrome. Journal of Pediatric Gastroenterology and Nutrition. 1998;26(5):496-499. Not sensitivity or specificity of an identified test. [pmid: 9586758].
Bonamico M, Culasso F, Pitzalis G, et al. Beta 2-microglobulin levels in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1990;11(3):330-336. Not sensitivity or specificity of an identified test. [pmid: 2246714].
Bonamico M, Mariani P, Danesi H M, et al. Prevalence and clinical picture of celiac disease in italian down syndrome patients: a multicenter study. Journal of Pediatric Gastroenterology and Nutrition. 2001;33(2):139-143. Not sensitivity or specificity of an identified test. [pmid: 11568513].
Bonamico M, Mariani P, Mazzilli M C, et al. Frequency and clinical pattern of celiac disease among siblings of celiac children. Journal of Pediatric Gastroenterology and Nutrition. 1996;23(2):159-163. Not sensitivity or specificity of an identified test. [pmid: 8856583].
Bonamico M, Mazzilli M C, Morellini M, et al. Expression of class II MHC antigens in the intestinal epithelium of pediatric celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1989;9(3):269-275. Not sensitivity or specificity of an identified test. [pmid: 2693680].
Bonamico M, Morellini M, Mariani P, et al. HLA antigens and antigliadin antibodies in coeliac disease. Disease Markers. 1991;9(6):313-317. Improper control group. [pmid: 1823310].
Bonamico M, Rasore-Quartino A, Mariani P, et al. Down syndrome and coeliac disease: Usefulness of antigliadin and antiendomysium antibodies. Acta Paediatr Int J Paediatr. 1996;85(12):1503-1505. Not sensitivity or specificity of an identified test.
Bonamico M, Scire G, Mariani P, et al. Short stature as the primary manifestation of monosymptomatic celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1992;14(1):12-16. Not sensitivity or specificity of an identified test. [pmid: 1573504].
Bonamico Margherita, Pasquino Anna M, Mariani Paolo, et al. Prevalence and clinical picture of celiac disease in Turner syndrome. Journal of Clinical Endocrinology and Metabolism. 2002;87(12):5495-5498. Not sensitivity or specificity of an identified test. [pmid: 12466343].
Bonelli Raphael M, Aschoff Andreas, Jirikowski Gustaf. Cerebrospinal fluid tissue transglutaminase in vascular dementia. Journal of the Neurological Sciences 2002;203-204207-209. Not sensitivity or specificity of an identified test
Bonelli Raphael M, Aschoff Andreas, Niederwieser Gerald, et al. Cerebrospinal fluid tissue transglutaminase as a biochemical marker for Alzheimer's disease. Neurobiology of Disease. 2002;11(1):106-110. Not sensitivity or specificity of an identified test. [pmid: 12460550].
Bonini S, Ruffilli A. Genetics of food allergy. Environ Toxicol Pharmacol. 1997;4(12):71-78. Not sensitivity or specificity of an identified test.
Boniotto M, Braida L, Ventura A, et al. Promoter polymorphisms of the CD14 gene in Italian patients with coeliac disease. Journal of Medical Genetics. 2003;40(9):E108. Not sensitivity or specificity of an identified test. [pmid: 12960224].
Boniotto Michele, Braida Laura, Spano Andrea, et al. Variant mannose-binding lectin alleles are associated with celiac disease. Immunogenetics. 2002;54(8):596-598. Not sensitivity or specificity of an identified test. [pmid: 12439623].
Bontems P, Deprettere A, Cadranel S, et al. The coeliac iceberg: A consensus in paediatrics. Acta Gastro-Enterol Belg. 2000;63(2):157-162. Not sensitivity or specificity of an identified test.
Bonvicini F, Zoli G, Maltarello M C, et al. Clinical applications of scanning electron microscopy in gastrointestinal diseases. Scanning Electron Microscopy. 1985;(Pt 3):1279-1294. Not sensitivity or specificity of an identified test. [pmid: 4070974].
Book L, Hart A, Black J, et al. Prevalence and clinical characteristics of celiac disease in Downs syndrome in a US study. American Journal of Medical Genetics. 2001;98(1):70-74. Improper control group. [pmid: 11426458].
Book Linda S. Diagnosing celiac disease in 2002: who, why, and how?. Pediatrics. 2002;109(5):952-954. Not sensitivity or specificity of an identified test. [pmid: 11986459].
Book Linda, Zone John J, Neuhausen Susan L. Prevalence of celiac disease among relatives of sib pairs with celiac disease in U.S. families. American Journal of Gastroenterology. 2003;98(2):377-381. Not sensitivity or specificity of an identified test. [pmid: 12591058].
Booth I W. The nutritional consequences of gastrointestinal disease in adolescence. Acta Paediatr Scand Suppl. 1991;80(373):91-102. Not sensitivity or specificity of an identified test. [pmid: 1927534].
Borch K, Grodzinsky E, Petersson F, et al. Prevalence of coeliac disease and relations to Helicobacter pylori infection and duodenitis in a Swedish adult population sample: A histomorphological and serological survey. Inflammopharmacology. 2000;8(4):341-350. Not sensitivity or specificity of an identified test.
Borg M, Phillips A D, Smith M W, et al. Enteric disease in early childhood inhibits microvillus expression by potential stem cells. Clinical Science (London, England - 1979). 1993;84(4):377-379. Not sensitivity or specificity of an identified test. [pmid: 8482042].
Borner H, Osman A A, Meergans T, et al. Isolation of antigens recognized by coeliac disease autoantibodies and their use in enzyme immunoassay of endomysium and reticulin antibody-positive human sera. Clinical and Experimental Immunology. 1996;106(2):344-350. Not sensitivity or specificity of an identified test. [pmid: 8918583]. [pmcid: 2200596].
Borth W, Chang V, Bishop P, et al. Lipoprotein (a) is a substrate for factor XIIIa and tissue transglutaminase. J Biol Chem. 1991;266(27):18149-18153. Not sensitivity or specificity of an identified test. [pmid: 1680857].
Bossart R, Henry K, Booth C C, et al. Subepithelial collagen in intestinal malabsorption. Gut. 1975;16(1):18-22. Not sensitivity or specificity of an identified test. [pmid: 49285]. [pmcid: 1410944].
Bossart R, Henry K, Doe W F, et al. Proceedings: Collagenous basement membrane thickening in jejunal biopsies from patients with adult coeliac disease. Gut. 1974;15(4):338. Not sensitivity or specificity of an identified test. [pmid: 4834565].
Bottaro G, Failla P, Rotolo N, et al. Changes in coeliac disease behaviour over the years. Acta Paediatrica (Oslo, Norway - 1992). 1993;82(67):566-568. Not sensitivity or specificity of an identified test. [pmid: 8338991].
Boudraa G, Hachelaf W, Benbouabdellah M et al. Prevalence of coeliac disease in diabetic children and their first- degree relatives in west Algeria: screening with serological markers. Acta Paediatrica (Oslo, Norway - 1992).Supplement 1996;41258–60. Improper control group
Bouguerra F, Babron M C, Eliaou J F, et al. Synergistic effect of two HLA heterodimers in the susceptibility to celiac disease in Tunisia. Genetic Epidemiology. 1997;14(4):413-422. Improper control group. [pmid: 9271713].
Bouguerra F, Dugoujon J M, Babron M C, et al. Susceptibility to coeliac disease in Tunisian children and GM immunoglobulin allotypes. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1999;26(4):293-297. Not sensitivity or specificity of an identified test. [pmid: 10457894].
Bouissou F, Meissner I, Konrad M, et al. Clinical implications from studies of HLA antigens in idiopathic nephrotic syndrome in children. Clin Nephrol. 1995;44(5):279-283. Not sensitivity or specificity of an identified test. [pmid: 8605706].
Bourgain C, Genin E, Holopainen P, et al. Use of closely related affected individuals for the genetic study of complex diseases in founder populations. American Journal of Human Genetics. 2001;68(1):154-159. Not sensitivity or specificity of an identified test. [pmid: 11102286]. [pmcid: 1234909].
Bourke M, O'Donovan M, Stevens F M, et al. Alpha 1-antitrypsin phenotypes in coeliac patients and a control population in the west of Ireland. Irish Journal of Medical Science. 1993;162(5):171-172. Not sensitivity or specificity of an identified test. [pmid: 8335451].
Bourne J T, Kumar P, Huskisson E C. Arthritis and coeliac disease. Ann Rheum Dis. 1985;44(9):592-598. Not sensitivity or specificity of an identified test. [pmid: 3876079]. [pmcid: 1001716].
Bowness J M, Tarr A H. Lipoprotein binding of crosslinked type III collagen aminopropeptide and fractions of its antigen in blood. Biochemical and Biophysical Research Communications. 1990;170(2):519-525. Not sensitivity or specificity of an identified test. [pmid: 1974421].
Bowness J M, Tarr A H, Wiebe R I. Transglutaminase-catalysed cross-linking: a potential mechanism for the interaction of fibrinogen, low density lipoprotein and arterial type III procollagen. Thromb Res. 1989;54(4):357-367. Not sensitivity or specificity of an identified test. [pmid: 2569775].
Bowron A, Moorghen M, Morgan J E, et al. Cost-effective strategy for the serological investigation of coeliac disease. Ann Clin Biochem. 2000;37(4):467-470. Improper control group. [pmid: 10902862].
Boy M F, La Nasa G, Balestrieri A, et al. Distribution of HLA-DPB1, -DQB1 -DQA1 alleles among Sardinian celiac patients. Disease Markers. 1995;12(3):199-204. Improper control group. [pmid: 8590546].
Boyce S, Michel S, Reichert U, et al. Reconstructed skin from cultured human keratinocytes and fibroblasts on a collagen-glycosaminoglycan biopolymer substrate. Skin Pharmacology - the Official Journal of the Skin Pharmacology Society. 1990;3(2):136-143. Not sensitivity or specificity of an identified test. [pmid: 2127678].
Boyd S, Collins B J, Bell P M, et al. Clinical presentation of coeliac disease in adult gastroenterological practice. Ulster Medical Journal. 1985;54(2):140-147. Not sensitivity or specificity of an identified test. [pmid: 4095802].
Boyton R J, Lohmann T, Londei M, et al. Glutamic acid decarboxylase T lymphocyte responses associated with susceptibility or resistance to type I diabetes: Analysis in disease discordant human twins, non-obese diabetic mice and HLA-DQ transgenic mice. Int Immunol. 1998;10(12):1765-1776. Not sensitivity or specificity of an identified test. [pmid: 9885897].
Brack M, Schroeder C, Fooke M, et al. IgM/IgA nephropathy in callitrichids: Antigen studies. Nephron. 1999;82(3):221-231. Not sensitivity or specificity of an identified test. [pmid: 10395994].
Brackin M N, Lewis R E, Brackin B T, et al. Progression of HIV infection is asssciated with HLA-DQ antigens in Caucasians and African Americans. Pathobiology. 1995;63(1):22-41. Not sensitivity or specificity of an identified test. [pmid: 7546273].
Bradgate M G, Redman C W, Rollason T P, et al. Binding of anti-EMA, AGF 4:48 and the lectin UEA-1 to human ovarian carcinomas: histological and clinical correlations. British Journal of Obstetrics and Gynaecology. 1989;96(7):854-860. Not sensitivity or specificity of an identified test. [pmid: 2475159].
Bradway S D, Bergey E J, Scannapieco F A, et al. Formation of salivary-mucosal pellicle: The role of transglutaminase. Biochem J. 1992;284(2):557-564. Not sensitivity or specificity of an identified test. [pmid: 1376115]. [pmcid: 1132674].
Braegger C P, MacDonald T T. The immunologic basis for celiac disease and related disorders. Seminars in Gastrointestinal Disease. 1996;7(3):124-133. Not sensitivity or specificity of an identified test. [pmid: 8817764].
Bramble M G, Watson A J, Scott J, et al. Clinical, biochemical and morphological responses of patients with villous atrophy to oral betamethasone valerate and clobetasone butyrate. Digestion. 1981;22(6):281-288. Not sensitivity or specificity of an identified test. [pmid: 7037504].
Bramble M G, Zucoloto S, Wright N A, et al. Acute gluten challenge in treated adult coeliac disease: a morphometric and enzymatic study. Gut. 1985;26(2):169-174. Not sensitivity or specificity of an identified test. [pmid: 3917964]. [pmcid: 1432436].
Brandborg L L. Histologic diagnosis of diseases of malabsorption. American Journal of Medicine. 1979;67(6):999-1006. Not sensitivity or specificity of an identified test. [pmid: 517556].
Brandborg L L, Goldberg S B, Breidenbach W C. Human coccidiosis--a possible cause of malabsorption. New England Journal of Medicine. 1970;283(24):1306-1313. Not sensitivity or specificity of an identified test. [pmid: 5478452].
Brandt L J, Locke G R, Olden K, et al. An evidence-based approach to the management of irritable bowel syndrome in North America. American Journal of Gastroenterology. 2002;97(11 SUPPL.):S1-S26. Not sensitivity or specificity of an identified test.
Brandtzaeg P. Immunologic basis for celiac disease, inflammatory bowel disease, and type B chronic gastritis. Curr Opin Gastroenterol. 1991;7(3):450-462. Not sensitivity or specificity of an identified test.
Brandtzaeg P, Valnes K, Scott H et al. The human gastrointestinal secretory immune system in health and disease. Scandinavian Journal of Gastroenterology.Supplement 1985;11417–38. Not sensitivity or specificity of an identified test
Branski D, Troncone R. Celiac disease: A reappraisal. Journal of Pediatrics. 1998;133(2):181-187. Not sensitivity or specificity of an identified test. [pmid: 9709703].
Branski D, Faber J, Shiner M. A comparison of small-intestinal mucosal biopsies in children obtained by blind suction capsule with those obtained by endoscopy. Journal of Pediatric Gastroenterology and Nutrition. 1996;22(2):194-196. Not sensitivity or specificity of an identified test. [pmid: 8642493].
Branski D, Faber J, Freier S, et al. Histologic evaluation of endoscopic versus suction biopsies of small intestinal mucosae in children with and without celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1998;27(1):6-11. Not sensitivity or specificity of an identified test. [pmid: 9779965].
Brautbar C, Freier S, Ashkenazi A, et al. Histocompatibility determinants in Israeli Jewish patients with coeliac disease: population and family study. Tissue Antigens. 1981;17(3):313-322. Not sensitivity or specificity of an identified test. [pmid: 6947507].
Brautbar C, Zlotogora J, Laufer N, et al. Do identical HLA-DR3 genes convey susceptibility to celiac disease and insulin dependent diabetes mellitus?. Tissue Antigens. 1984;23(1):58-60. Not sensitivity or specificity of an identified test. [pmid: 6608164].
Breen E G, Coughlan G, Connolly C E, et al. Coeliac proctitis. Scandinavian Journal of Gastroenterology. 1987;22(4):471-477. Not sensitivity or specificity of an identified test. [pmid: 3602927].
Brett P M, Yiannakou J Y, Morris M A, et al. A pedigree-based linkage study of coeliac disease: failure to replicate previous positive findings. Annals of Human Genetics. 1998;62(Pt 1):25-32. Not sensitivity or specificity of an identified test. [pmid: 9659975].
Brett P M, Yiannakou J Y, Morris M A, et al. Common HLA alleles, rather than rare mutants, confer susceptibility to coeliac disease. Annals of Human Genetics. 1999;63(Pt 3):217-225. Unable to extract data. [pmid: 10738534].
Brewster D, Pakorny C S. Investigating the child with malnutrition. Med Today. 2001;2(7):88-93. Not sensitivity or specificity of an identified test.
Brocchi E, Corazza G R, Caletti G, et al. Endoscopic demonstration of loss of duodenal folds in the diagnosis of celiac diasease. New Engl J Med. 1988;319(12):741-744. Not sensitivity or specificity of an identified test. [pmid: 3412397].
Brocchi E, Tomassetti P, Misitano B, et al. Endoscopic markers in adult coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(3):177-182. Not sensitivity or specificity of an identified test. [pmid: 11990389].
Broekaert D, Leigh I M, Lane E B, et al. An immunohistochemical and histochemical study of cytokeratin, involucrin and transglutaminase in seborrhoeic keratosis. Archives of Dermatological Research. 1993;285(8):482-490. Not sensitivity or specificity of an identified test. [pmid: 7506018].
Broekaert D, Pattin C, Coucke P, et al. Keratinization of middle ear cholesteatomas. I. A histochemical study of epidermal transglutaminase. European Archives of Oto-Rhino-Laryngology - Official Journal of the European Federation of Oto-Rhino-Laryngological Societies (Eufos) - Affiliated With the German Society for Oto-Rhino-Laryngolog. 1990;247(5):312-317. Not sensitivity or specificity of an identified test.
Brooks A P, Harrington C I. Acquired ichthyosis and toxic epidermal necrolysis and mesenteric reticulum cell sarcoma and malabsorption. Br Med J. 1977;2(6089):739-740. Not sensitivity or specificity of an identified test. [pmid: 334333]. [pmcid: 1632106].
Brooks F P, Powell K C, Cerda J J. Variable clinical course of adult celiac disease. Archives of Internal Medicine. 1966;117(6):789-794. Not sensitivity or specificity of an identified test. [pmid: 5327218].
Brow J R, Parker F, Weinstein W M, et al. The small intestinal mucosa in dermatitis herpetiformis. I. Severity and distribution of the small intestinal lesion and associated malabsorption. Gastroenterology. 1971;60(3):355-361. Not sensitivity or specificity of an identified test. [pmid: 5554078].
Brown M R, Lillibridge C B. When to think of celiac disease: the classical features of gluten sensitive enteropathy are absent. Clinical Pediatrics. 1975;14(1):76-82. Not sensitivity or specificity of an identified test. [pmid: 46189].
Brucato A, Franceschini F, Gasparini M, et al. Isolated congenital complete heart block: Longterm outcome of mothers, maternal antibody specificity and immunogenetic background. J Rheumatol. 1995;22(3):533-540. Not sensitivity or specificity of an identified test. [pmid: 7783076].
Bruce G, Woodley J F, Swan C H J. Breakdown of gliadin peptides by intestinal brush borders from coeliac patients. Gut. 1984;25(9):919-924. Not sensitivity or specificity of an identified test. [pmid: 6381246]. [pmcid: 1432494].
Bruce S E, Bjarnason I, Peters T J. Human jejunal transglutaminase: demonstration of activity, enzyme kinetics and substrate specificity with special relation to gliadin and coeliac disease. Clinical Science (London, England - 1979). 1985;68(5):573-579. Not sensitivity or specificity of an identified test. [pmid: 2858282].
Bruges-Armas J, Martinez-Laso J, Martins B, et al. HLA in the Azores Archipelago: Possible presence of Mongoloid genes. Tissue Antigens. 1999;54(4):349-359. Not sensitivity or specificity of an identified test. [pmid: 10551418].
Bruno C J, Batts K P, Ahlquist D A. Evidence against flat dysplasia as a regional field defect in small bowel adenocarcinoma associated with celiac sprue. Mayo Clinic Proceedings. 1997;72(4):320-322. Not sensitivity or specificity of an identified test. [pmid: 9121177].
Brusco G, Di Stefano M, Corazza G R. Increased red cell distribution width and coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2000;32(2):128-130. Not sensitivity or specificity of an identified test. [pmid: 10975787].
Brusco G, Izzi L, Corazza G R. Tissue transglutaminase antibodies for coeliac disease screening. Italian Journal of Gastroenterology and Hepatology. 1998;30(5):496-497. Improper control group. [pmid: 9836104].
Brusco G, Muzi P, Ciccocioppo R, et al. Transglutaminase and coeliac disease: endomysial reactivity and small bowel expression. Clinical and Experimental Immunology. 1999;118(3):371-375. Not sensitivity or specificity of an identified test. [pmid: 10594554]. [pmcid: 1905435].
Bryant D A, Mintz E D, Puhr N D, et al. Colonic epithelial lymphocytosis associated with an epidemic of chronic diarrhea. American Journal of Surgical Pathology. 1996;20(9):1102-1109. Not sensitivity or specificity of an identified test. [pmid: 8764747].
Brzechwa-Ajdukiewicz A, McCarthy C F, Austad W, et al. Carcinoma, villous atrophy, and steatorrhoea. Gut. 1966;7(6):572-577. Not sensitivity or specificity of an identified test. [pmid: 5957507]. [pmcid: 1552634].
Buchan A M, Grant S, Brown J C, et al. A quantitative study of enteric endocrine cells in celiac sprue. Journal of Pediatric Gastroenterology and Nutrition. 1984;3(5):665-671. Not sensitivity or specificity of an identified test. [pmid: 6150077].
Bucht A, Soderstrom K, Esin S, et al. Analysis of gamma delta V region usage in normal and diseased human intestinal biopsies and peripheral blood by polymerase chain reaction (PCR) and flow cytometry. Clinical and Experimental Immunology. 1995;99(1):57-64. Not sensitivity or specificity of an identified test. [pmid: 7813110]. [pmcid: 1534135].
Buckley D B, English J, Molloy W, et al. Dermatitis herpetiformis: a review of 119 cases. Clinical and Experimental Dermatology. 1983;8(5):477-487. Not sensitivity or specificity of an identified test. [pmid: 6641006].
Budzynski A Z. Fibrinogen and fibrin: biochemistry and pathophysiology. Critical Reviews in Oncology/Hematology. 1986;6(2):97-146. Not sensitivity or specificity of an identified test. [pmid: 2878736].
Bugawan T L, Angelini G, Larrick J, et al. A combination of a particular HLA-DP beta allele and an HLA-DQ heterodimer confers susceptibility to coeliac disease. Nature. 1989;339(6224):470-473. Not sensitivity or specificity of an identified test. [pmid: 2498667].
Bugawan T L, Horn G T, Long C M, et al. Analysis of HLA-DP allelic sequence polymorphism using the in vitro enzymatic DNA amplification of DP-alpha and DP-beta loci. J Immunol. 1988;141(11):4024-4030. Not sensitivity or specificity of an identified test. [pmid: 2460556].
Bullen A W, Hall R, Gowland G, et al. Hyposplenism, adult coeliac disease, and autoimmunity. Gut. 1981;22(1):28-33. Not sensitivity or specificity of an identified test. [pmid: 7461474]. [pmcid: 1419299].
Bunce M, Taylor C J, Welsh K I. Rapid HLA-DQB typing by eight polymerase chain reaction amplifications with sequence-specific primers (PCR-SSP). Human Immunology. 1993;37(4):201-206. Not sensitivity or specificity of an identified test. [pmid: 7905469].
Buommino E, Morelli F, Metafora S, et al. Porin from Pseudomonas aeruginosa induces apoptosis in an epithelial cell line derived from rat seminal vesicles. Infection and Immunity. 1999;67(9):4794-4800. Not sensitivity or specificity of an identified test. [pmid: 10456933]. [pmcid: 96811].
Burgin-Wolff A, Berger R, Gaze H, et al. IgG, IgA and IgE gliadin antibody determinations as screening test for untreated coeliac disease in children, a multicentre study. European Journal of Pediatrics. 1989;148(6):496-502. Improper control group. [pmid: 2663505].
Burgin-Wolff A, Bertele R M, Berger R, et al. A reliable screening test for childhood celiac disease: fluorescent immunosorbent test for gliadin antibodies. A prospective multicenter study. Journal of Pediatrics. 1983;102(5):655-660. Serology <1990. [pmid: 6341529].
Burgin-Wolff A, Dahlbom I, Hadziselimovic F, et al. Antibodies against human tissue transglutaminase and endomysium in diagnosing and monitoring coeliac disease. Scandinavian Journal of Gastroenterology. 2002;37(6):685-691. Improper control group. [pmid: 12126247].
Burgin-Wolff A, Gaze H, Hadziselimovic F, et al. Antigliadin and antiendomysium antibody determination for coeliac disease. Archives of Disease in Childhood. 1991;66(8):941-947. Improper control group. [pmid: 1819255].
Burgin-Wolff A, Hernandez R, Just M, et al. Immunofluorescent antibodies against gliadin: a screening test for coeliac disease. Helvetica Paediatrica Acta. 1976;31(45):375-380. Serology <1990. [pmid: 797680].
Burhol P G, Myren J. Dehydrogenase activity and mucosal measurements in jejunal biopsies from patients with gastrointestinal diseases. Scandinavian Journal of Gastroenterology. 1966;1(2):142-148. Not sensitivity or specificity of an identified test. [pmid: 5966090].
Burk K, Bosch S, Muller C A et al. Sporadic cerebellar ataxia associated with gluten sensitivity. Brain 2001;A Journal of Neurology; 124(Pt 5):1013–1019. Not sensitivity or specificity of an identified test
Burke V, Colebatch J H, Anderson C M, et al. Association of pancreatic insufficiency and chronic neutropenia in childhood. Archives of Disease in Childhood. 1967;42(222):147-157. Not sensitivity or specificity of an identified test. [pmid: 6024465].
Burnie J. A possible immunological mechanism for the pathogenesis of dermatitis herpetiformis with reference to coeliac disease. Clinical and Experimental Dermatology. 1980;5(4):451-463. Not sensitivity or specificity of an identified test. [pmid: 7261463].
Burrows R, Leiva L, Burgueno M, et al. Bone mineral density (BMD) in children with celiac disease (CD): Its relation to puberty and calcium intake. Nutr Res. 1999;19(4):493-499. Not sensitivity or specificity of an identified test.
Busch H J, Jirikowski G F, Aschoff A P et al. Actin in semithin sections of myocardial biopsies as a tool to visualize myofibrillary degradation in humans. Cellular and Molecular Biology (Noisy-Le-Grand, France) 2001;47 Online Pubol89-ol94. Not sensitivity or specificity of an identified test
Bushara K O, Goebel S U, Shill H, et al. Gluten sensitivity in sporadic and hereditary cerebellar ataxia. Annals of Neurology. 2001;49(4):540-543. Not sensitivity or specificity of an identified test. [pmid: 11310636].
Buts J P, Morin C L, Roy C C, et al. One-hour blood xylose test: a reliable index of small bowel function. Journal of Pediatrics. 1978;92(5):729-733. Not sensitivity or specificity of an identified test. [pmid: 641621].
Butterworth Jeffrey R, Cooper Brian T, Rosenberg William M C, et al. The role of hemochromatosis susceptibility gene mutations in protecting against iron deficiency in celiac disease. Gastroenterology. 2002;123(2):444-449. Not sensitivity or specificity of an identified test. [pmid: 12145797].
Buxman M M. The role of enzymatic coupling of drugs to proteins in induction of drug specific antibodies. J Invest Dermatol. 1979;73(3):256-258. Not sensitivity or specificity of an identified test. [pmid: 38285].
Buxman M M, Wuepper K D. Keratin cross-linking and epidermal transglutaminase. A review with observations on the histochemical and immunochemical localization of the enzyme. Journal of Investigative Dermatology 1975;65(1):107-112. Not sensitivity or specificity of an identified test.
Buyse I, Sandkuyl L A, Zamani Ghabanbasani M, et al. Association of particular HLA class II alleles, haplotypes and genotypes with susceptibility to IDDM in the Belgian population. Diabetologia. 1994;37(8):808-817. Not sensitivity or specificity of an identified test. [pmid: 7988783].
Cacciamani Tiziana, Virgili Samantha, Centurelli Matteo, et al. Specific methylation of the CpG-rich domains in the promoter of the human tissue transglutaminase gene. Gene. 2002;297(12):103-112. Not sensitivity or specificity of an identified test. [pmid: 12384291].
Cacciari E, Salardi S, Lazzari R, et al. Short stature and celiac disease: a relationship to consider even in patients with no gastrointestinal tract symptoms. Journal of Pediatrics. 1983;103(5):708-711. Not sensitivity or specificity of an identified test. [pmid: 6631596].
Cacciari E, Salardi S, Volta U, et al. Antigliadin antibodies in coeliac children with short stature. Lancet. 1985;2(84698470):1434. Not sensitivity or specificity of an identified test. [pmid: 2867433].
Cacciari E, Salardi S, Volta U, et al. Can antigliadin antibody detect symptomless coeliac disease in children with short stature?. Lancet. 1985;1(8444):1469-1471. Serology <1990. [pmid: 2867433].
Caffarelli C, Romanini E, Caruana P, et al. Clinical food hypersensitivity: the relevance of duodenal immunoglobulin E-positive cells. Pediatric Research. 1998;44(4):485-490. Not sensitivity or specificity of an identified test. [pmid: 9773835].
Caffrey C, Hitman G A, Niven M J, et al. HLA-DP and coeliac disease: family and population studies. Gut. 1990;31(6):663-667. Not sensitivity or specificity of an identified test. [pmid: 1974234]. [pmcid: 1378492].
Calabuig M, Torregosa R, Polo P, et al. Serological markers and celiac disease: a new diagnostic approach?. Journal of Pediatric Gastroenterology and Nutrition. 1990;10(4):435-442. Improper control group. [pmid: 2193137].
Calam J, Ellis A, Dockray G J. Identification and measurement of molecular variants of cholecystokinin in duodenal mucosa and plasma. Diminished concentrations in patients with celiac disease. Journal of Clinical Investigation. 1982;69(1):218-225. Not sensitivity or specificity of an identified test. [pmid: 7033291]. [pmcid: 371185].
Calero P, Ribes-Koninckx C, Albiach V, et al. IgA antigliadin antibodies as a screening method for nonovert celiac disease in children with insulin-dependent diabetes mellitus. Journal of Pediatric Gastroenterology and Nutrition. 1996;23(1):29-33. Not sensitivity or specificity of an identified test. [pmid: 8811520].
Camarero C, Eiras P, Asensio A, et al. Intraepithelial lymphocytes and coeliac disease: permanent changes in CD3-/CD7+ and T cell receptor gammadelta subsets studied by flow cytometry. Acta Paediatrica (Oslo, Norway - 1992). 2000;89(3):285-290. Not sensitivity or specificity of an identified test. [pmid: 10772275].
Cameron E A, Stewart J A, West K P, et al. Coeliac disease presenting with intraperitoneal haemorrhage. European Journal of Gastroenterology & Hepatology. 1998;10(7):619-620. Not sensitivity or specificity of an identified test. [pmid: 9855089].
Cameron P U, Mallal S A, French M A H, et al. Major histocompatibility complex genes influence the outcome of HIV infection: Ancestral haplotypes with C4 null alleles explain diverse HLA associations. Hum Immunol. 1990;29(4):282-295. Not sensitivity or specificity of an identified test. [pmid: 1981061].
Campbell C B, Roberts R K, Cowen A E. The changing clinical presentation of coeliac disease in adults. Medical Journal of Australia. 1977;1(4):89-93. Not sensitivity or specificity of an identified test. [pmid: 557720].
Campbell R D, Dodds A W, Porter R R. The binding of human complement component C4 to antibody-antigen aggregates. Biochemical Journal. 1980;189(1):67-80. Not sensitivity or specificity of an identified test. [pmid: 6906229]. [pmcid: 1161918].
Candi E, Paradisi A, Terrinoni A, et al. Role of transglutaminase 5 in epidermis. Minerva Biotecnol. 2002;14(2):155-158. Not sensitivity or specificity of an identified test.
Candi Eleonora, Oddi Sergio, Paradisi Andrea, et al. Expression of transglutaminase 5 in normal and pathologic human epidermis. Journal of Investigative Dermatology. 2002;119(3):670-677. Not sensitivity or specificity of an identified test. [pmid: 12230511].
Caraglia M, Marra M, Giuberti G, et al. The role of eukaryotic initiation factor 5A in the control of cell proliferation and apoptosis. Amino Acids. 2001;20(2):91-104. Not sensitivity or specificity of an identified test. [pmid: 11332455].
Caraglia Michele, Marra Monica, Giuberti Gaia, et al. Theophylline-induced apoptosis is paralleled by protein kinase A-dependent tissue transglutaminase activation in cancer cells. Journal of Biochemistry. 2002;132(1):45-52. Not sensitivity or specificity of an identified test. [pmid: 12097159].
Carbonara A O, DeMarchi M, van Loghem E, et al. Gm markers in celiac disease. Human Immunology. 1983;6(2):91-95. Not sensitivity or specificity of an identified test. [pmid: 6601100].
Carbonnel F, D'Almagne H, Lavergne A, et al. The clinicopathological features of extensive small intestinal CD4 T cell infiltration. Gut. 1999;45(5):662-667. Not sensitivity or specificity of an identified test. [pmid: 10517900]. [pmcid: 1727728].
Carbonnel F, Grollet-Bioul L, Brouet J C, et al. Are complicated forms of celiac disease cryptic T-cell lymphomas?. Blood. 1998;92(10):3879-3886. Not sensitivity or specificity of an identified test. [pmid: 9808581].
Carcassi C, Cottoni F, Floris L, et al. HLA haplotypes and class II molecular alleles in Sardinian and Italian patients with pemphigus vulgaris. Tissue Antigens. 1996;48(6):662-667. Not sensitivity or specificity of an identified test. [pmid: 9008308].
Cardaba B, Cortegano I, Flondo F, et al. Genetic restrictions in olive pollen allergy. J Allergy Clin Immunol. 2000;105(2 I):292-298. Not sensitivity or specificity of an identified test. [pmid: 10669850].
Cardaba B, de Pablo R, Vilches C, et al. Allergy to olive pollen: T-cell response from olive allergic patients is restricted by DR7-DQ2 antigens. Clin Exp Allergy. 1996;26(3):316-322. Not sensitivity or specificity of an identified test. [pmid: 8729669].
Cardaba B, Ezendam J, Gallardo S, et al. DR2 antigens are associated with severity of disease in toxic oil syndrome (TOS). Tissue Antigens. 2000;55(2):110-117. Not sensitivity or specificity of an identified test. [pmid: 10746782].
Cardaba B, Vilches C, Martin E, et al. DR7 and DQ2 are positively associated with immunoglobulin-E response to the main antigen of olive pollen (Ole e I) in allergic patients. Hum Immunol. 1993;38(4):293-299. Not sensitivity or specificity of an identified test. [pmid: 7908014].
Cariello L, Velasco P T, Wilson J, et al. Probing the transglutaminase-mediated, posttranslational modification of proteins during development. Biochemistry. 1990;29(21):5103-5108. Not sensitivity or specificity of an identified test. [pmid: 1974146].
Carlsson A K, Axelsson I E, Borulf S K, et al. Serological screening for celiac disease in healthy 2.5-year-old children in Sweden. Pediatrics. 2001;107(1):42-45. Not sensitivity or specificity of an identified test. [pmid: 11134432].
Carlsson A K, Axelsson I E, Borulf S K, et al. Prevalence of IgA-antiendomysium and IgA-antigliadin autoantibodies at diagnosis of insulin-dependent diabetes mellitus in Swedish children and adolescents. Pediatrics. 1999;103(6 Pt 1):1248-1252. Not sensitivity or specificity of an identified test. [pmid: 10353937].
Carlsson A, Axelsson I, Borulf S, et al. Prevalence of IgA-antigliadin antibodies and IgA-antiendomysium antibodies related to celiac disease in children with Down syndrome. Pediatrics. 1998;101(2):272-275. Not sensitivity or specificity of an identified test. [pmid: 9445503].
Carlsson Annelie K, Lindberg Bengt A, Bredberg Anders C A, et al. Enterovirus infection during pregnancy is not a risk factor for celiac disease in the offspring. Journal of Pediatric Gastroenterology and Nutrition. 2002;35(5):649-652. Not sensitivity or specificity of an identified test. [pmid: 12454580].
Carnicer J, Farre C, Varea V, et al. Prevalence of coeliac disease in Down Syndrome. European Journal of Gastroenterology & Hepatology. 2001;13(3):263-267. Not sensitivity or specificity of an identified test. [pmid: 11293446].
Carpenter C B. Autoimmunity and HLA. Journal of Clinical Immunology. 1982;2(3):157-165. Not sensitivity or specificity of an identified test. [pmid: 6811606].
Carpino F, Ceccamea A, Magliocca F M, et al. Scanning electron microscopy of jejunal biopsies in patients with untreated and treated coeliac disease. Acta Paediatrica Scandinavica. 1985;74(5):775-781. Unable to extract data. [pmid: 4050426].
Carr K E, Toner P G. Surface studies of acute radiation injury in the mouse intestine. Virchows Archiv. B- Cell Pathology 1972;11(3):201-210. Not sensitivity or specificity of an identified test.
Carroccio A, Cavataio F, Iacono G, et al. IgA antiendomysial antibodies on the umbilical cord in diagnosing celiac disease. Sensitivity, specificity, and comparative evaluation with the traditional kit. Scandinavian Journal of Gastroenterology. 1996;31(8):759-763. Improper control group. [pmid: 8858743].
Carroccio A, Custro N, Montalto G, et al. Evidence of transient IgA anti-endomysial antibody positivity in a patient with Graves' disease. Digestion. 1999;60(1):86-88. Not sensitivity or specificity of an identified test. [pmid: 9892805].
Carroccio A, Giannitrapani L, Soresi M, et al. Guinea pig transglutaminase immunolinked assay does not predict coeliac disease in patients with chronic liver disease. Gut. 2001;49(4):506-511. Not sensitivity or specificity of an identified test. [pmid: 11559647]. [pmcid: 1728470].
Carroccio A, Iacono G, Montalto G, et al. Pancreatic insufficiency in celiac disease is not dependent on nutritional status. Digestive Diseases and Sciences. 1994;39(10):2235-2242. Not sensitivity or specificity of an identified test. [pmid: 7924748].
Carroccio A, Iannitto E, Cavataio F, et al. Sideropenic anemia and celiac disease: one study, two points of view. Digestive Diseases and Sciences. 1998;43(3):673-678. Not sensitivity or specificity of an identified test. [pmid: 9539667].
Carroccio A, Iovanna J L, Iacono G, et al. Pancreatitis-associated protein in patients with celiac disease: serum levels and immunocytochemical localization in small intestine. Digestion. 1997;58(2):98-103. Not sensitivity or specificity of an identified test. [pmid: 9144297].
Carroccio Antonio, Iannitto Emilio, Di Prima, et al. Screening for celiac disease in non-Hodgkin's lymphoma patients: a serum anti-transglutaminase-based approach. Digestive Diseases and Sciences. 2003;48(8):1530-1536. Not sensitivity or specificity of an identified test. [pmid: 12924648].
Carswell F, Ferguson A. Food antibodies in serum--a screening test for coeliac disease. Archives of Disease in Childhood. 1972;47(254):594-596. Not sensitivity or specificity of an identified test. [pmid: 5065303].
Carswell F, Ferguson A. Plasma food antibodies during withdrawal and reintroduction of dietary gluten in coeliac disease. Arch Dis Child. 1973;48(8):583-586. Not sensitivity or specificity of an identified test. [pmid: 4798761].
Carswell F, Gibson A A, McAllister T A. Giardiasis and coeliac disease. Archives of Disease in Childhood. 1973;48(6):414-418. Not sensitivity or specificity of an identified test. [pmid: 4712770].
Carter M J, Willcocks M M, Mitchison H C, et al. Is a persistent adenovirus infection involved in coeliac disease?. Gut. 1989;30(11):1563-1567. Not sensitivity or specificity of an identified test. [pmid: 2557269]. [pmcid: 1434325].
Caruso C, Candore G, Modica M A, et al. Immunoglobulin heavy chain allotypes in a sample of Sicilian patients with celiac disease. Experimental and Clinical Immunogenetics. 1991;8(1):1-5. Not sensitivity or specificity of an identified test. [pmid: 1910856].
Casadio R, Polverini E, Mariani P, et al. The structural basis for the regulation of tissue transglutaminase by calcium ions. European Journal of Biochemistry / Febs. 1999;262(3):672-679. Not sensitivity or specificity of an identified test. [pmid: 10411627].
Case April, Stein Ross L. Kinetic analysis of the action of tissue transglutaminase on peptide and protein substratest. Biochemistry. 2003;42(31):9466-9481. Not sensitivity or specificity of an identified test. [pmid: 12899634].
Casellas F, de Torres I, Malagelada J R. Improved screening for intestinal villous atrophy by D-xylose breath test. Digestive Diseases and Sciences. 2000;45(1):18-22. Not sensitivity or specificity of an identified test. [pmid: 10695607].
Casellas F, de Torres I, Malagelada J-R. Follow-up of celiac disease with D-xylose breath test. Digestive Diseases and Sciences. 1996;41(10):2106-2111. Not sensitivity or specificity of an identified test. [pmid: 8888728].
Casellas F, Sardi J, de Torres I, et al. Hydrogen breath test with D-xylose for celiac disease screening is as useful in the elderly as in other age groups. Digestive Diseases and Sciences. 2001;46(10):2201-2205. Not sensitivity or specificity of an identified test. [pmid: 11680597].
Caspary W F, Winckler K, Lankisch P G, et al. Influence of exocrine and endocrine pancreatic function on intestinal brush border enaymatic activities. Gut. 1975;16(2):89-92. Not sensitivity or specificity of an identified test. [pmid: 1092602]. [pmcid: 1411003].
Cassiman J J, van der, Schueren B et al. Qualitative and quantitative differences in spreading of human fibroblasts on various protein coats. Modulation by treatment of the cells with amines. Journal of Cell Science 1982;5479–95. Not sensitivity or specificity of an identified test
Castellino F, Scaglione N, Grosso S B, et al. A novel method for detecting IgA endomysial antibodies by using human umbilical vein endothelial cells. European Journal of Gastroenterology & Hepatology. 2000;12(1):45-49. Improper control group. [pmid: 10656209].
Castro M, Crino A, Papadatou B, et al. Down Syndrome and celiac disease: the prevalence of high IgA-antigliadin antibodies and HLA-DR and DQ antigens in trisomy 21. Journal of Pediatric Gastroenterology and Nutrition. 1993;16(3):265-268. Improper control group. [pmid: 8492253].
Cataldo F, Lio D, Marino V, et al. Cytokine genotyping (TNF and IL-10) in patients with celiac disease and selective IgA deficiency. American Journal of Gastroenterology. 2003;98(4):850-856. Not sensitivity or specificity of an identified test. [pmid: 12738467].
Cataldo F, Marino V, Bottaro G, et al. Celiac disease and selective immunoglobulin A deficiency. Journal of Pediatrics. 1997;131(2):306-308. Not sensitivity or specificity of an identified test. [pmid: 9290622].
Cataldo F, Marino V, Ventura A, et al. Prevalence and clinical features of selective immunoglobulin A deficiency in coeliac disease: an Italian multicentre study. Italian Society of Paediatric Gastroenterology and Hepatology (SIGEP) and “Club del Tenue” Working Groups on Coeliac Disease. Gut. 1998;42(3):362-365. Not sensitivity or specificity of an identified test. [pmid: 9577342]. [pmcid: 1727042].
Cataldo F, Ventura A, Lazzari R, et al. Antiendomysium antibodies and coeliac disease: solved and unsolved questions. An Italian multicentre study. Acta Paediatrica (Oslo, Norway - 1992). 1995;84(10):1125-1131. Improper control group. [pmid: 8563223].
Cataldo Francesco, Marino Vincenzo. Increased prevalence of autoimmune diseases in first-degree relatives of patients with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 2003;36(4):470-473. Not sensitivity or specificity of an identified test. [pmid: 12658037].
Catassi C. Intestinal permeability tests: Research or diagnosis?. Pediatr Rev Commun. 1993;7(3):202-205. Not sensitivity or specificity of an identified test.
Catassi C, Fabiani E. The spectrum of coeliac disease in children. Bailliere's Clinical Gastroenterology. 1997;11(3):485-507. Not sensitivity or specificity of an identified test. [pmid: 9448912].
Catassi C, Doloretta Macis M, Ratsch I M, et al. The distribution of DQ genes in the Saharawi population provides only a partial explanation for the high celiac disease prevalence. Tissue Antigens. 2001;58(6):402-406. Improper control group. [pmid: 11929591].
Catassi C, Fabiani E, Gasparin M, et al. Quantitative antigliadin antibody measurement in clinical practice: an Italian multicentre study. SIGEP Working Group on Quantitative AGA Standardization. Italian Journal of Gastroenterology and Hepatology. 1999;31(5):366-370. Improper control group. [pmid: 10470593].
Catassi C, Fabiani E, Ratsch I M, et al. Celiac disease in the general population: Should we treat asymptomatic cases?. Journal of Pediatric Gastroenterology and Nutrition. 1997;24(5):S10-S13. Not sensitivity or specificity of an identified test. [pmid: 9161968].
Catassi C, Fabiani E, Ratsch I M et al. The coeliac iceberg in Italy. A multicentre antigliadin antibodies screening for coeliac disease in school-age subjects. Acta Paediatrica (Oslo, Norway - 1992).Supplement 1996;41229–35. Not sensitivity or specificity of an identified test
Catassi C, Fanciulli G, D'Appello A R, et al. Antiendomysium versus antigliadin antibodies in screening the general population for coeliac disease. Scandinavian Journal of Gastroenterology. 2000;35(7):732-736. Improper control group. [pmid: 10972177].
Catassi C, Fornaroli F, Fasano A. Celiac disease: From basic immunology to bedside practice. Clin Appl Immunol Rev. 2002;3(12):61-71. Not sensitivity or specificity of an identified test.
Catassi C, Guerrieri A, Bartolotta E. Antigliadin antibodies at onset of diabetes in children. Lancet. 1987;2(8551):158. Not sensitivity or specificity of an identified test. [pmid: 2885618].
Catassi C, Ratsch I M, Fabiani E, et al. High prevalence of undiagnosed coeliac disease in 5280 Italian students screened by antigliadin antibodies. Acta Paediatrica (Oslo, Norway - 1992). 1995;84(6):672-676. Not sensitivity or specificity of an identified test. [pmid: 7670254].
Catassi C, Ratsch I M, Fabiani E, et al. Coeliac disease in the year 2000: exploring the iceberg. Lancet. 1994;343(8891):200-203. Not sensitivity or specificity of an identified test. [pmid: 7904667].
Catassi C, Ratsch I-M, Gandolfi L, et al. Why is coeliac disease endemic in the people of the Sahara?. Lancet. 1999;354(9179):647-648. Not sensitivity or specificity of an identified test. [pmid: 10466670].
Catassi C, Rossini M, Ratsch I M, et al. Dose dependent effects of protracted ingestion of small amounts of gliadin in coeliac disease children: a clinical and jejunal morphometric study. Gut. 1993;34(11):1515-1519. Not sensitivity or specificity of an identified test. [pmid: 8244135]. [pmcid: 1374413].
Catassi Carlo, Fabiani Elisabetta, Corrao Giovanni, et al. Risk of non-Hodgkin lymphoma in celiac disease. Jama - the Journal of the American Medical Association. 2002;287(11):1413-1419. Not sensitivity or specificity of an identified test. [pmid: 11903028].
Catino M, Tumini S, Mezzetti A, et al. Coeliac disease and diabetes mellitus in children: A non casual association. Diabetes Nutr Metab Clin Exp. 1998;11(5):296-302. Not sensitivity or specificity of an identified test.
Cavataio F, Iacono G, Carroccio A, et al. Diagnostic accuracy of a new stick micromethod with which to measure antigliadin antibodies. Journal of Pediatric Gastroenterology and Nutrition. 1994;19(4):401-402. Not sensitivity or specificity of an identified test. [pmid: 7876993].
Cellier C, Cervoni J P, Patey N, et al. Gluten-free diet induces regression of T-cell activation in the rectal mucosa of patients with celiac disease. American Journal of Gastroenterology. 1998;93(9):1527-1530. Not sensitivity or specificity of an identified test. [pmid: 9732937].
Cellier C, Cuillerier E, Patey-Mariaud de, et al. Push enteroscopy in celiac sprue and refractory sprue. Gastrointestinal Endoscopy. 1999;50(5):613-617. Not sensitivity or specificity of an identified test. [pmid: 10536314].
Cellier C, Delabesse E, Helmer C, et al. Refractory sprue, coeliac disease, and enteropathy-associated T-cell lymphoma. French Coeliac Disease Study Group. Lancet. 2000;356(9225):203-208. Not sensitivity or specificity of an identified test. [pmid: 10963198].
Cellier C, Patey N, Mauvieux L, et al. Abnormal intestinal intraepithelial lymphocytes in refractory sprue. Gastroenterology. 1998;114(3):471-481. Not sensitivity or specificity of an identified test. [pmid: 9496937].
Cerio R, Griffiths C E, Cooper K D, et al. Characterization of factor XIIIa positive dermal dendritic cells in normal and inflamed skin. British Journal of Dermatology. 1989;121(4):421-431. Not sensitivity or specificity of an identified test. [pmid: 2576222].
Cerio R, Rao B K, Spaull J, et al. An immunohistochemical study of fibrous papule of the nose: 25 cases. Journal of Cutaneous Pathology. 1989;16(4):194-198. Not sensitivity or specificity of an identified test. [pmid: 2571624].
Cerio R, Spaull J, Jones E W. Histiocytoma cutis: a tumour of dermal dendrocytes (dermal dendrocytoma). British Journal of Dermatology. 1989;120(2):197-206. Not sensitivity or specificity of an identified test. [pmid: 2564281].
Cerio R, Spaull J, Oliver G F, et al. A study of factor XIIIa and MAC 387 immunolabeling in normal and pathological skin. American Journal of Dermatopathology. 1990;12(3):221-233. Not sensitivity or specificity of an identified test. [pmid: 1972317].
Cervetto J L, Ramonet M, Nahmod L H, et al. Giardiasis. Functional, immunological and histological study of the small bowel. Therapeutic trial with a single dose of tinidazole. Arquivos De Gastroenterologia. 1987;24(2):102-112. Not sensitivity or specificity of an identified test. [pmid: 3333125].
Cetinkaya H, Altintas B, Palabiyikoglu M, et al. Diagnostic value of antigliadin antibodies in gluten sensitive enteropathy. Turk J Gastroenterol. 1997;8(1):89-93. Improper control group.
Chakrabarti S, Kobayashi K S, Flavell R A, et al. Impaired membrane resealing and autoimmune myositis in synaptotagmin VII-deficient mice. J Cell Biol. 2003;162(4):543-549. Not sensitivity or specificity of an identified test. [pmid: 12925704].
Challacombe D N. Screening tests for coeliac disease. Archives of Disease in Childhood. 1995;73(1):3-4. Not sensitivity or specificity of an identified test. [pmid: 7639545].
Challacombe D N, Dawkins P D. Increased tissue concentrations of histamine in the duodenal mucosa of children with coeliac disease. Journal of Clinical Pathology. 1982;35(6):596-598. Not sensitivity or specificity of an identified test. [pmid: 7085909]. [pmcid: 497731].
Challacombe D N, McDonald D T, Wheeler E E. A quantitative assessment of jejunal villous damage in coeliac disease, using the mucosal index. Hepato-Gastroenterology. 1983;30(3):113-115. Unable to extract data. [pmid: 6884972].
Challacombe D N, Mecrow I K, Elliott K, et al. Changing infant feeding practices and declining incidence of coeliac disease in West Somerset. Arch Dis Child. 1997;77(3):206-209. Not sensitivity or specificity of an identified test. [pmid: 9370896].
Challacombe D N, Sandler M, Southgate J. Decreased duodenal monoamine oxidase activity in coeliac disease. Archives of Disease in Childhood. 1971;46(246):213-215. Not sensitivity or specificity of an identified test. [pmid: 5576033].
Champliaud M F, Burgeson R E, Jin W, et al. cDNA cloning and characterization of sciellin, a LIM domain protein of the keratinocyte cornified envelope. Journal of Biological Chemistry. 1998;273(47):31547-31554. Not sensitivity or specificity of an identified test. [pmid: 9813070].
Chan K N, Philips A D, Walker-Smith J A, et al. Serum interleukin-2 receptor in infants and young children. Acta Paediatr Int J Paediatr. 1995;84(2):151-155. Not sensitivity or specificity of an identified test.
Chan K N, Phillips A D, Mirakian R, et al. Endomysial antibody screening in children. Journal of Pediatric Gastroenterology and Nutrition. 1994;18(3):316-320. Improper control group. [pmid: 8057214].
Chandra R K, Sahni S. Immunological aspects of gluten intolerance. Nutrition Reviews. 1981;39(3):117-120. Not sensitivity or specificity of an identified test. [pmid: 7027094].
Chapman B L, Henry K, Paice F, et al. A new technique for examining intestinal biopsies. Gut. 1972;13(10):846. Not sensitivity or specificity of an identified test. [pmid: 5087096].
Chapman B L, Henry K, Paice F, et al. A new technique for examining intestinal biopsies. Gut. 1973;14(11):905-909. Not sensitivity or specificity of an identified test. [pmid: 4761612]. [pmcid: 1412852].
Chapoval S P, Iijima K, Marietta E V, et al. Allergic inflammatory response to short ragweed allergenic extract in HLA-DQ transgenic mice lacking CD4 gene. J Immunol. 2002;168(2):890-899. Not sensitivity or specificity of an identified test. [pmid: 11777987].
Charron D. HLA class II disease associations: Molecular basis. J Autoimmun. 1992;5(Suppl A):45-53. Not sensitivity or specificity of an identified test. [pmid: 1503635].
Chartrand L J, Russo P A, Duhaime A G, et al. Wheat starch intolerance in patients with celiac disease. Journal of the American Dietetic Association. 1997;97(6):612-618. Not sensitivity or specificity of an identified test. [pmid: 9183321].
Chatzicostas Costantinos, Roussomoustakaki Maria, Drygiannakis Dimitrios, et al. Primary biliary cirrhosis and autoimmune cholangitis are not associated with coeliac disease in Crete. Bmc Gastroenterology Electronic Resource. 2002;2(1):5. Not sensitivity or specificity of an identified test. [pmid: 11914139]. [pmcid: 102761].
Chauhan B, Santiago L, Hutcheson P S, et al. Evidence for the involvement of two different MHC class II regions in susceptibility or protection in allergic bronchopulmonary aspergillosis. J Allergy Clin Immunol. 2000;106(4):723-729. Not sensitivity or specificity of an identified test. [pmid: 11031343].
Cheli R, Giacosa A. Inflammatory cell count and identification in specific duodenitis. (Celiac disease, Whipple's disease and Crohn's disease). Comparison with jejunal findings. Endoscopy. 1977;9(3):147-151. Unable to extract data. [pmid: 71989].
Cheli R, Giacosa A. Does malabsorption occur in atrophic duodenitis?. Hepato-Gastroenterology. 1984;31(6):272-273. Not sensitivity or specificity of an identified test. [pmid: 6519638].
Chen D, Ueda R, Harding F, et al. Characterization of HLA DR3/DQ2 transgenic mice: A potential humanized animal model for autoimmune disease studies. Eur J Immunol. 2003;33(1):172-182. Not sensitivity or specificity of an identified test. [pmid: 12594846].
Chen J S, Mehta K. Tissue transglutaminase: an enzyme with a split personality. International Journal of Biochemistry & Cell Biology. 1999;31(8):817-836. Not sensitivity or specificity of an identified test. [pmid: 10481269].
Chen S, Lin F, Iismaa S, et al. Alpha1-adrenergic receptor signaling via Gh is subtype specific and independent of its transglutaminase activity. Journal of Biological Chemistry. 1996;271(50):32385-32391. Not sensitivity or specificity of an identified test. [pmid: 8943303].
Chen Z, Dudek N, Wijburg O, et al. A 320-kilobase artificial chromosome encoding the human HLA DR3-DQ2 MHC haplotype confers HLA restriction in transgenic mice. J Immunol. 2002;168(6):3050-3056. Not sensitivity or specificity of an identified test. [pmid: 11884478].
Cheng Hong, Wang Jun, Zhang Chuan, et al. Clinicopathologic study of mucosa-associated lymphoid tissue lymphoma in gastroscopic biopsy. World Journal of Gastroenterology - Wjg. 2003;9(6):1270-1272. Not sensitivity or specificity of an identified test. [pmid: 12800238].
Cheong K Y, Allcock R J N, Eerligh P, et al. Localization of central MHC genes influencing type I diabetes. Hum Immunol. 2001;62(12):1363-1370. Not sensitivity or specificity of an identified test. [pmid: 11756005].
Chernavsky Alejandra C, Rubio Andrea E, Vanzulli Silvia, et al. Evidences of the involvement of Bak, a member of the Bcl-2 family of proteins, in active coeliac disease. Autoimmunity. 2002;35(1):29-37. Not sensitivity or specificity of an identified test. [pmid: 11908704].
Chhaya S U, Shankarkumar U. HLA antigen distribution in Jain population from Mumbai, Maharashtra, India. Indian J Med Res. 2001;113(July):25-29. Not sensitivity or specificity of an identified test. [pmid: 11762203].
Chiantore M V, Giandomenico V, De Luca L M. Carcinoma cell lines resistant for growth inhibition and apoptosis to retinoic acid are responsive to 4-hydroxy-phenyl-retinamide: correlation with tissue transglutaminase. Biochemical and Biophysical Research Communications. 1999;254(3):636-641. Not sensitivity or specificity of an identified test. [pmid: 9920792].
Chicz R M, Lane W S, Robinson R A, et al. Self-peptides bound to the type I diabetes associated class II MHC molecules HLA-DQ1 and HLA-DQ8. Int Immunol. 1994;6(11):1639-1649. Not sensitivity or specificity of an identified test. [pmid: 7865457].
Chimenti C, Pieroni M, Frustaci A. Celiac disease in idiopathic dilated cardiomyopathy. Ital Heart J. 2001;2(9):658-659. Not sensitivity or specificity of an identified test. [pmid: 11666093].
Chin R L, Sander H W, Brannagan T H, et al. Celiac neuropathy. Neurology. 2003;60(10):1581-1585. Not sensitivity or specificity of an identified test. [pmid: 12771245].
Chirdo F G, Rumbo M, Anon M C, et al. Presence of high levels of non-degraded gliadin in breast milk from healthy mothers. Scandinavian Journal of Gastroenterology. 1998;33(11):1186-1192. Not sensitivity or specificity of an identified test. [pmid: 9867098].
Chirdo F G, Zwirner N W, Rumbo M, et al. In vitro presentation of gliadin-derived peptides by different cell lines. Clin Chim Acta. 2002;317(12):151-158. Not sensitivity or specificity of an identified test. [pmid: 11814470].
Choate K A, Khavari P A. Sustainability of keratinocyte gene transfer and cell survival in vivo. Human Gene Therapy. 1997;8(8):895-901. Not sensitivity or specificity of an identified test. [pmid: 9322868].
Chorzelski T P, Beutner E H, Sulej J, et al. IgA anti-endomysium antibody. A new immunological marker of dermatitis herpetiformis and coeliac disease. British Journal of Dermatology. 1984;111(4):395-402. Serology <1990. [pmid: 6435666].
Chorzelski T P, Jablonska S, Chadzynska M, et al. IgA endomysium antibody in children with dermatitis herpetiformis treated with gluten-free diet. Pediatric Dermatology. 1986;3(4):291-294. Not sensitivity or specificity of an identified test. [pmid: 3774647].
Chorzelski T P, Sulej J, Tchorzewska H et al. IgA class endomysium antibodies in dermatitis herpetiformis and coeliac disease. Annals of the New York Academy of Sciences 1983;420325–334. Not sensitivity or specificity of an identified test
Chou K-Y, Chan M, Bias W B. Differential expression of the down-regulatory function of CD8 cells in trichosanthin-induced immunosuppression and its genetic control in humans. Eur J Immunogenet. 1996;23(1):29-40. Not sensitivity or specificity of an identified test. [pmid: 8834921].
Chou S M, Taniguchi A, Wang H S, et al. Serpin=serine protease-like complexes within neurofilament conglomerates of motoneurons in amyotrophic lateral sclerosis. Journal of the Neurological Sciences. 1998;160(Suppl 1):s73-s79. Not sensitivity or specificity of an identified test. [pmid: 9851654].
Chowdhury Z A, Barsigian C, Chalupowicz G D, et al. Colocalization of tissue transglutaminase and stress fibers in human vascular smooth muscle cells and human umbilical vein endothelial cells. Experimental Cell Research. 1997;231(1):38-49. Not sensitivity or specificity of an identified test. [pmid: 9056410].
Christenson M J, LaRosa T, Jung M, et al. Hypomorphic C4B*15 variant of the fourth component of complement. Febs Lett. 1990;260(2):183-186. Not sensitivity or specificity of an identified test. [pmid: 1688812].
Christiansen O B. The possible role of classical human leukocyte antigens in recurrent miscarriage. Am J Reprod Immunol. 1999;42(2):110-115. Not sensitivity or specificity of an identified test. [pmid: 10476693].
Christou H, Connors J M, Ziotopoulou M, et al. Cord blood leptin and insulin-like growth factor levels are independent predictors of fetal growth. Journal of Clinical Endocrinology and Metabolism. 2001;86(2):935-938. Not sensitivity or specificity of an identified test. [pmid: 11158070].
Chrysomali E, Papanicolaou S I, Dekker N P, et al. Benign neural tumors of the oral cavity: a comparative immunohistochemical study. Oral Surgery, Oral Medicine, Oral Pathology, Oral Radiology, and Endodontics. 1997;84(4):381-390. Not sensitivity or specificity of an identified test. [pmid: 9347502].
Chuang C K, Shen Y C, Wu J H, et al. Immunobiologic, cytogenetic and drug response features of a newly established cell line (SCRC-1) from renal small cell carcinoma. Journal of Urology. 2000;163(3):1016-1021. Not sensitivity or specificity of an identified test. [pmid: 10688041].
Chumpitazi B F, Boussaid A, Pelloux H, et al. Diagnosis of congenital toxoplasmosis by immunoblotting and relationship with other methods. Journal of Clinical Microbiology. 1995;33(6):1479-1485. Not sensitivity or specificity of an identified test. [pmid: 7650171]. [pmcid: 228200].
Chun W, Lesort M, Tucholski J, et al. Tissue transglutaminase selectively modifies proteins associated with truncated mutant huntingtin in intact cells. Neurobiology of Disease. 2001;8(3):391-404. Not sensitivity or specificity of an identified test. [pmid: 11442349].
Chun W, Lesort M, Tucholski J, et al. Tissue transglutaminase does not contribute to the formation of mutant huntingtin aggregates. Journal of Cell Biology. 2001;153(1):25-34. Not sensitivity or specificity of an identified test. [pmid: 11285271].
Chung M H. Analysis of small bowel biopsies. A clinical and histopathological correlation. Yonsei Medical Journal 1968;9(2):105-115. Unable to extract data.
Chung Wu, Mathews K P. Generation of drug metabolite antigenicity in the intestinal mucosa. Immunopharmacology. 1986;12(1):53-58. Not sensitivity or specificity of an identified test. [pmid: 2875976].
Chuttani H K, Jain K, Misra R C. Small bowel in typhoid fever. Gut. 1971;12(9):709-712. Not sensitivity or specificity of an identified test. [pmid: 4999718]. [pmcid: 1411789].
Chuttani H K, Kasthuri D, Misra R C. Course and prognosis of tropical sprue. Journal of Tropical Medicine and Hygiene. 1968;71(4):96-99. Not sensitivity or specificity of an identified test. [pmid: 5649292].
Ciacci C, Cirillo M, Giorgetti G, et al. Low plasma cholesterol: a correlate of nondiagnosed celiac disease in adults with hypochromic anemia. American Journal of Gastroenterology. 1999;94(7):1888-1891. Not sensitivity or specificity of an identified test. [pmid: 10406254].
Ciacci C, Di Vizio D, Seth R, et al. Selective reduction of intestinal trefoil factor in untreated coeliac disease. Clinical and Experimental Immunology. 2002;130(3):526-531. Not sensitivity or specificity of an identified test. [pmid: 12452845]. [pmcid: 1906543].
Ciacci C, Iavarone A, Mazzacca G, et al. Depressive symptoms in adult coeliac disease. Scandinavian Journal of Gastroenterology. 1998;33(3):247-250. Not sensitivity or specificity of an identified test. [pmid: 9548616].
Ciacci C, Squillante A, Rendina D, et al. Helicobacter pylori infection and peptic disease in coeliac disease. European Journal of Gastroenterology & Hepatology. 2000;12(12):1283-1287. Not sensitivity or specificity of an identified test. [pmid: 11192316].
Ciacci Carolina, Cirillo Massimo, Cavallaro Raimondo, et al. Long-term follow-up of celiac adults on gluten-free diet: prevalence and correlates of intestinal damage. Digestion. 2002;66(3):178-185. Not sensitivity or specificity of an identified test. [pmid: 12481164].
Ciampolini M, Bini S. Serum lipids in celiac children. Journal of Pediatric Gastroenterology and Nutrition. 1991;12(4):459-460. Not sensitivity or specificity of an identified test. [pmid: 1865279].
Ciampolini M, Bini S, Orsi A. Microflora persistence on duodenojejunal flat or normal mucosa in time after a meal in children. Physiol Behav. 1996;60(6):1551-1556. Not sensitivity or specificity of an identified test. [pmid: 8946504].
Ciccocioppo R, D'Alo S, Di Sabatino A, et al. Mechanisms of villous atrophy in autoimmune enteropathy and coeliac disease. Clinical and Experimental Immunology. 2002;128(1):88-93. Not sensitivity or specificity of an identified test. [pmid: 11982595]. [pmcid: 1906355].
Ciccocioppo R, Di Sabatino A, Parroni R, et al. Cytolytic mechanisms of intraepithelial lymphocytes in coeliac disease (CoD). Clinical and Experimental Immunology. 2000;120(2):235-240. Not sensitivity or specificity of an identified test. [pmid: 10792370]. [pmcid: 1905653].
Ciccocioppo R, Di Sabatino A, Parroni R, et al. Increased enterocyte apoptosis and Fas-Fas ligand system in celiac disease. American Journal of Clinical Pathology. 2001;115(4):494-503. Not sensitivity or specificity of an identified test. [pmid: 11293896].
Ciclitira P J. Recent advances in coeliac disease. Clin Med. 2003;3(2):166-169. Not sensitivity or specificity of an identified test. [pmid: 12737376].
Ciclitira P J, Ellis H J. In vivo gluten ingestion in coeliac disease. Digestive Diseases (Basel, Switzerland). 1998;16(6):337-340. Not sensitivity or specificity of an identified test. [pmid: 10207218].
Ciclitira P J, Hall M A. Coeliac disease. Baillieres Clin Gastroenterol. 1990;4(1):43-59. Not sensitivity or specificity of an identified test. [pmid: 1976395].
Ciclitira P J, Sturgess R. Clinicopathologic mechanisms in celiac disease. Curr Opin Gastroenterol. 1992;8(2):262-267. Not sensitivity or specificity of an identified test.
Ciclitira P J, Cerio R, Ellis H J. Evaluation of a gliadin-containing gluten-free product in coeliac patients. Hum Nutr Clin Nutr. 1985;39(4):303-308. Not sensitivity or specificity of an identified test. [pmid: 3930437].
Ciclitira P J, Ellis H J, Evans D J. A solid-phase radioimmunoassay for measurement of circulating antibody titres to wheat gliadin and its subfractions in patients with adult coeliac disease. Journal of Immunological Methods. 1983;62(2):231-239. Not sensitivity or specificity of an identified test. [pmid: 6193198].
Ciclitira P J, Ellis H J, Venning V A. Circulating antibodies to gliadin subfractions in dermatitis herpetiformis and linear IgA dermatosis of adults and children. Clin Exp Dermatol. 1986;11(5):502-509. Not sensitivity or specificity of an identified test. [pmid: 3545571].
Ciclitira P J, Ellis H J, Evans D J, et al. A radioimmunoassay for wheat gliadin to assess the suitability of gluten free foods for patients with coeliac disease. Clinical and Experimental Immunology. 1985;59(3):703-708. Not sensitivity or specificity of an identified test. [pmid: 3987095]. [pmcid: 1576931].
Ciclitira P J, Ellis H J, Wood G M, et al. Secretion of gliadin antibody by coeliac jejunal mucosal biopsies cultured in vitro. Clinical and Experimental Immunology. 1986;64(1):119-124. Not sensitivity or specificity of an identified test. [pmid: 3731523]. [pmcid: 1542153].
Ciclitira P J, Evans D J, Fagg N L, et al. Clinical testing of gliadin fractions in coeliac patients. Clinical Science (London, England - 1979). 1984;66(3):357-364. Not sensitivity or specificity of an identified test. [pmid: 6692666].
Ciclitira P J, Hooper L B, Ellis H J, et al. Gliadin antibody production by small intestinal lymphocytes from patients with coeliac disease. International Archives of Allergy and Applied Immunology. 1989;89(23):246-249. Not sensitivity or specificity of an identified test. [pmid: 2759717].
Ciclitira P J, King A L, Fraser J S. AGA technical review on Celiac Sprue. American Gastroenterological Association. Gastroenterology. 2001;120(6):1526-1540. Not sensitivity or specificity of an identified test. [pmid: 11313324].
Ciclitira P J, Nelufer J M, Ellis H J, et al. The effect of gluten on HLA-DR in the small intestinal epithelium of patients with coeliac disease. Clinical and Experimental Immunology. 1986;63(1):101-104. Not sensitivity or specificity of an identified test. [pmid: 3514010]. [pmcid: 1577323].
Ciclitira P J, Stewart J, Evan G, et al. Expression of c-myc oncogene in coeliac disease. Journal of Clinical Pathology. 1987;40(3):307-311. Not sensitivity or specificity of an identified test. [pmid: 3549790]. [pmcid: 1140905].
Ciclitira Paul J, Moodie Simon J. Transition of care between paediatric and adult gastroenterology. Coeliac disease. Best Practice & Research.Clinical. Gastroenterology. 2003;17(2):181-195. Not sensitivity or specificity of an identified test.
Cinek O, Dr caron, umnik Z, et al. NEUROD polymorphism Ala45Thr is associated with Type 1 diabetes mellitus in Czech children. Diabetes Res Clin Pract. 2003;60(1):49-56. Not sensitivity or specificity of an identified test. [pmid: 12639765].
Cipolli M, Valletta E A, Zampieri C, et al. Increased serum levels of antigliadin antibodies in cystic fibrosis. Acta Paediatrica (Oslo, Norway - 1992). 1993;82(1):95-97. Not sensitivity or specificity of an identified test. [pmid: 8453232].
Citron B A, Gregory E J, Steigerwalt D S, et al. Regulation of the dual function tissue transglutaminase/Galpha(h) during murine neuromuscular development: Gene and enzyme isoform expression. Neurochem Int. 2000;37(4):337-349. Not sensitivity or specificity of an identified test. [pmid: 10825574].
Citron B A, SantaCruz K S, Davies P J, et al. Intron-exon swapping of transglutaminase mRNA and neuronal Tau aggregation in Alzheimer's disease. Journal of Biological Chemistry. 2001;276(5):3295-3301. Not sensitivity or specificity of an identified test. [pmid: 11013236].
Citron Bruce A, Suo Zhiming, SantaCruz Karen, et al. Protein crosslinking, tissue transglutaminase, alternative splicing and neurodegeneration. Neurochemistry International. 2002;40(1):69-78. Not sensitivity or specificity of an identified test. [pmid: 11738473].
Clark M L, Senior J R. Small gut mucosal activites of pyrimidine precursor enzymes in celiac disease. Gastroenterology. 1969;56(5):887-894. Not sensitivity or specificity of an identified test. [pmid: 5782301].
Clegg D O, Pincus S H, Zone J J, et al. Circulating HLA-DR bearing T cells: correlation with genetic rather than clinical variables. Journal of Rheumatology. 1986;13(5):870-874. Not sensitivity or specificity of an identified test. [pmid: 3493345].
Clemente M G, Congia M, De Virgiliis S. The laboratory in autoimmune diseases. Ital J Pediat. 2002;28(1):12-18. Not sensitivity or specificity of an identified test.
Clemente M G, Musu M P, Frau F, et al. Immune reaction against the cytoskeleton in coeliac disease. Gut. 2000;47(4):520-526. Not sensitivity or specificity of an identified test. [pmid: 10986212]. [pmcid: 1728086].
Clemente Maria, Grazia Musu, Maria Paola, et al. Antitissue transglutaminase antibodies outside celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 2002;34(1):31-34. Test-specific exclusion. [pmid: 11753161].
Clerget-Darpoux F, Bouguerra F, Kastally R, et al. High risk genotypes for celiac disease. Comptes Rendus De L'academie Des Sciences. Serie Iii, Sciences De La Vie. 1994;317(10):931-936. Improper control group.
Clerici N, Fernandez M, Saiz I, et al. Human leukocyte antigen alleles and haplotypes associated with selective immunoglobulin A deficiency in Spanish pediatric patients. Journal of Pediatric Gastroenterology and Nutrition. 1993;16(4):381-386. Not sensitivity or specificity of an identified test. [pmid: 8315545].
Clot F, Babron M C. Genetics of celiac disease. Molecular Genetics and Metabolism. 2000;71(12):76-80. Review article. [pmid: 11001799].
Clot F, Babron M C, Percopo S, et al. Study of two ectopeptidases in the susceptibility to celiac disease: two newly identified polymorphisms of dipeptidylpeptidase IV. Journal of Pediatric Gastroenterology and Nutrition. 2000;30(4):464-466. Not sensitivity or specificity of an identified test. [pmid: 10776965].
Clot F, Fulchignoni-Lataud M C, Renoux C, et al. Linkage and association study of the CTLA-4 region in coeliac disease for Italian and Tunisian populations. Tissue Antigens. 1999;54(5):527-530. Not sensitivity or specificity of an identified test. [pmid: 10599894].
Clot F, Gianfrani C, Babron M C, et al. HLA-DR53 molecules are associated with susceptibility to celiac disease and selectively bind gliadin-derived peptides. Immunogenetics. 1999;49(9):800-807. Improper control group. [pmid: 10398807].
Clot F, Gianfrani C, Babron M-C, et al. Response. Immunogenetics. 2000;51(3):251. Not sensitivity or specificity of an identified test. [pmid: 10752633].
Cluysenaer O J J, Van Tongeren J H M. The natural history of coeliac sprue, and factors which may influence it. Neth J Med. 1978;21(1):35-43. Not sensitivity or specificity of an identified test. [pmid: 634415].
Cluysenaer O J, Schillings P H, van Tongeren J H. Mucosal lesions and malabsorption in celiac sprue. Journal of Clinical Gastroenterology. 1982;4(5):425-429. Unable to extract data. [pmid: 7175148].
Cobain T J, Stuckey M S, McCluskey J. The coexistence of IgA deficiency and 21-hydroxylase deficiency marked by specific MHC supratypes. Ann New York Acad Sci. 1985;458(-):76-84. Not sensitivity or specificity of an identified test. [pmid: 3879134].
Cogulu O, Ozkinay F, Gunduz C, et al. Celiac disease in children with down syndrome: Importance of follow-up and serologic screening. Pediatr Int. 2003;45(4):395-399. Not sensitivity or specificity of an identified test. [pmid: 12911473].
Cohen I, Anderson B. Immunochemical characterization of the transglutaminase-catalyzed polymer of activated platelets. Thrombosis Research. 1987;47(4):409-416. Not sensitivity or specificity of an identified test. [pmid: 2889277].
Cole S G, Kagnoff M F. Celiac disease. Annual Review of Nutrition 1985;5241–266. Not sensitivity or specificity of an identified test
Collier P M, Wojnarowska F, Welsh K, et al. Adult linear IgA disease and chronic bullous disease of childhood: The association with human lymphocyte antigens Cw7, B8, DR3 and tumour necrosis factor influences disease expression. Br J Dermatol. 1999;141(5):867-875. Not sensitivity or specificity of an identified test. [pmid: 10583169].
Collighan R, Cortez J, Griffin M. The biotechnological applications of transglutaminases. Minerva Biotecnol. 2002;14(2):143-148. Not sensitivity or specificity of an identified test.
Collin P. New diagnostic findings in coeliac disease. Annals of Medicine. 1999;31(6):399-405. Not sensitivity or specificity of an identified test. [pmid: 10680854].
Collin P. Serologic screening for coeliac disease--time for tissue transglutaminase test?. Italian Journal of Gastroenterology and Hepatology. 1998;30(5):498-499. Not sensitivity or specificity of an identified test. [pmid: 9836105].
Collin P, Maki M. Celiac disease--even a neurological disorder. Journal of Pediatric Gastroenterology and Nutrition. 1997;24(1):116-117. Not sensitivity or specificity of an identified test. [pmid: 9093998].
Collin P, Hallstrom O, Maki M, et al. Atypical coeliac disease found with serologic screening. Scandinavian Journal of Gastroenterology. 1990;25(3):245-250. Not sensitivity or specificity of an identified test. [pmid: 2320942].
Collin P, Helin H, Maki M, et al. Follow-up of patients positive in reticulin and gliadin antibody tests with normal small-bowel biopsy findings. Scandinavian Journal of Gastroenterology. 1993;28(7):595-598. Not sensitivity or specificity of an identified test. [pmid: 8362211].
Collin P, Kaukinen K, Maki M. Clinical features of celiac disease today. Digestive Diseases (Basel, Switzerland). 1999;17(2):100-106. Not sensitivity or specificity of an identified test. [pmid: 10545715].
Collin P, Korpela M, Hallstrom O, et al. Rheumatic complaints as a presenting symptom in patients with coeliac disease. Scandinavian Journal of Rheumatology. 1992;21(1):20-23. Not sensitivity or specificity of an identified test. [pmid: 1570482].
Collin P, Pirttila T, Nurmikko T, et al. Celiac disease, brain atrophy, and dementia. Neurology. 1991;41(3):372-375. Not sensitivity or specificity of an identified test. [pmid: 2006004].
Collin P, Rasmussen M, Kyronpalo S, et al. The hunt for coeliac disease in primary care. Qjm - Monthly Journal of the Association of Physicians. 2002;95(2):75-77. Not sensitivity or specificity of an identified test. [pmid: 11861953].
Collin P, Reunala T, Rasmussen M, et al. High incidence and prevalence of adult coeliac disease. Augmented diagnostic approach. Scandinavian Journal of Gastroenterology. 1997;32(11):1129-1133. Not sensitivity or specificity of an identified test. [pmid: 9399394].
Collin P, Salmi J, Hallstrom O, et al. High frequency of coeliac disease in adult patients with Type-I diabetes. Scandinavian Journal of Gastroenterology. 1989;24(1):81-84. Not sensitivity or specificity of an identified test. [pmid: 2784589].
Collin P, Salmi J, Hallstrom O, et al. Autoimmune thyroid disorders and coeliac disease. European Journal of Endocrinology / European Federation of Endocrine Societies. 1994;130(2):137-140. Not sensitivity or specificity of an identified test. [pmid: 8130887].
Collin P, Vilska S, Heinonen P K, et al. Infertility and coeliac disease. Gut. 1996;39(3):382-384. Not sensitivity or specificity of an identified test. [pmid: 8949641]. [pmcid: 1383343].
Collin Pekka, Reunala Timo. Recognition and management of the cutaneous manifestations of celiac disease: a guide for dermatologists. American Journal of Clinical Dermatology. 2003;4(1):13-20. Not sensitivity or specificity of an identified test. [pmid: 12477369].
Collin Pekka, Kaukinen Katri, Valimaki Matti, et al. Endocrinological disorders and celiac disease. Endocrine Reviews. 2002;23(4):464-483. Not sensitivity or specificity of an identified test. [pmid: 12202461].
Collin Pekka, Syrjanen Jaana, Partanen Jukka, et al. Celiac disease and HLA DQ in patients with IgA nephropathy. American Journal of Gastroenterology. 2002;97(10):2572-2576. Improper control group. [pmid: 12385441].
Collins A L, Brookfield D S, Hyde I, et al. Small bowel biopsy. Archives of Disease in Childhood. 1985;60(11):1082-1085. Not sensitivity or specificity of an identified test. [pmid: 4073940].
Collins B J, Bell P M, Thomson J M, et al. Dietary history and nutritional state in treated coeliac patients. Journal of the Royal Society of Medicine. 1986;79(4):206-209. Not sensitivity or specificity of an identified test. [pmid: 3701766]. [pmcid: 1290275].
Colombel J F, Mascart-Lemone F, Nemeth J, et al. Jejunal immunoglobulin and antigliadin antibody secretion in adult coeliac disease. Gut. 1990;31(12):1345-1349. Not sensitivity or specificity of an identified test. [pmid: 2265776]. [pmcid: 1378754].
Colombel J F, Torpier G, Janin A, et al. Activated eosinophils in adult coeliac disease: evidence for a local release of major basic protein. Gut. 1992;33(9):1190-1194. Not sensitivity or specificity of an identified test. [pmid: 1427370]. [pmcid: 1379484].
Colombo Gualtiero, Buffa Roberto, Bardella Maria, et al. Anti-inflammatory effects of alpha-melanocyte-stimulating hormone in celiac intestinal mucosa. Neuroimmunomodulation. 2003;10(4):208-216. Not sensitivity or specificity of an identified test.
Colonna M, Mantovani W, Corazza G R, et al. Reassessment of HLA association with celiac disease in special reference to the DP association. Human Immunology. 1990;29(4):263-274. Improper control group. [pmid: 2286538].
Colston K W, Mackay A G, Finlayson C, et al. Localisation of vitamin D receptor in normal human duodenum and in patients with coeliac disease. Gut. 1994;35(9):1219-1225. Not sensitivity or specificity of an identified test. [pmid: 7959227]. [pmcid: 1375697].
Combarros O, Infante J, Lopez-Hoyos M, et al. Celiac disease and idiopathic cerebellar ataxia. Neurology. 2000;54(12):2346. Not sensitivity or specificity of an identified test. [pmid: 10881272].
Commo S, Bernard B A. Immunohistochemical analysis of tissue remodelling during the anagen-catagen transition of the human hair follicle. British Journal of Dermatology. 1997;137(1):31-38. Not sensitivity or specificity of an identified test. [pmid: 9274622].
Commo S, Bernard B A. Immunohistochemical analysis of tissue remodelling during the anagen-catagen transition of the human hair follicle. G Ital Dermatol Venereol. 2002;137(2 SUPPL. 1):3-11. Not sensitivity or specificity of an identified test.
Congdon P J, Fiddler G I, Littlewood J M, et al. Coeliac disease associated with congenital heart disease. Archives of Disease in Childhood. 1982;57(1):78-79. Not sensitivity or specificity of an identified test. [pmid: 7065700].
Congdon P, Mason M K, Smith S, et al. Small-bowel mucosa in asymptomatic children with celiac disease. Mucosal changes with gluten-free diets. American Journal of Diseases of Children (1960). 1981;135(2):118-121. Unable to extract data. [pmid: 7468543].
Congia M, Cucca F, Frau F, et al. A gene dosage effect of the DQA1*0501/DQB1*0201 allelic combination influences the clinical heterogeneity of celiac disease. Human Immunology. 1994;40(2):138-142. Improper control group. [pmid: 7928445].
Congia M, Frau F, Lampis R, et al. A high frequency of the A30, B18, DR3, DRw52, DQw2 extended haplotype in Sardinian celiac disease patients: further evidence that disease susceptibility is conferred by DQ A1*0501, B1*0201. Tissue Antigens. 1992;39(2):78-83. Improper control group. [pmid: 1349446].
Conkling P R, Achyuthan K E, Greenberg C S, et al. Human mononuclear phagocyte transglutaminase activity cross-links fibrin. Thrombosis Research. 1989;55(1):57-68. Not sensitivity or specificity of an identified test. [pmid: 2571199].
Connon J J, McFarland J, Kelly A. Acute abdominal complications of coeliac disease. Scandinavian Journal of Gastroenterology. 1975;10(8):843-846. Not sensitivity or specificity of an identified test. [pmid: 1105763].
Conrad Karsten, Schmechta Helmut, Klafki Agnes, et al. Serological differentiation of inflammatory bowel diseases. European Journal of Gastroenterology & Hepatology. 2002;14(2):129-135. Not sensitivity or specificity of an identified test. [pmid: 12352222].
Contini D, Torti A, Monti M, et al. A freeze-fracture study of the enteropathy associated with dermatitis herpetiformis: a comparative investigation with coeliac disease. Journal of Cutaneous Pathology. 1986;13(4):293-300. Not sensitivity or specificity of an identified test. [pmid: 3771874].
Cook D M, Evans N, Lloyd A, et al. Coeliac disease. Reappraisal of clinical diagnosis. Archives of Disease in Childhood. 1971;46(249):705-708. Not sensitivity or specificity of an identified test. [pmid: 5118061].
Cook H B, Burt M J, Collett J A, et al. Adult coeliac disease: prevalence and clinical significance. Journal of Gastroenterology and Hepatology. 2000;15(9):1032-1036. Not sensitivity or specificity of an identified test. [pmid: 11059933].
Cooke W T, Asquith P. Introduction and definition. Clin Gastroenterol. 1974;3(1):3-10. Not sensitivity or specificity of an identified test. [pmid: 4599070].
Coombs R R, Kieffer M, Fraser D R, et al. Naturally developing antibodies to wheat gliadin fractions and to other cereal antigens in rabbits, rats and guinea pigs on normal laboratory diets. International Archives of Allergy and Applied Immunology. 1983;70(3):200-204. Not sensitivity or specificity of an identified test. [pmid: 6826231].
Cooper Arthur J L, Jeitner Thomas M, Gentile Vittorio, et al. Cross linking of polyglutamine domains catalyzed by tissue transglutaminase is greatly favored with pathological-length repeats: does transglutaminase activity play a role in (CAG)(n)/Q(n)-expansion diseases?. Neurochemistry International. 2002;40(1):53-67. Not sensitivity or specificity of an identified test. [pmid: 11738472].
Cooper A J L, Sheu K-F, Burke J R, et al. Inhibition of alpha-ketoglutarate-and pyruvate dehydrogenase complexes in E. coli by a glutathione S-transferase containing a pathological length poly- Q domain: A possible role of energy deficit in neurological diseases associated with poly-Q expansions?. Age. 1998;21(1):25-30. Not sensitivity or specificity of an identified test.
Cooper A J L, Sheu K-F, Burke J R, et al. Transglutaminase-catalyzed inactivation of glyceraldehyde 3-phosphate dehydrogenase and alpha-ketoglutarate dehydrogenase complex by polyglutamine domains of pathological length. Proc Natl Acad Sci U S A. 1997;94(23):12604-12609. Not sensitivity or specificity of an identified test. [pmid: 9356496]. [pmcid: 25053].
Cooper A J, Sheu K F, Burke J R, et al. Pathogenesis of inclusion bodies in (CAG)n/Qn-expansion diseases with special reference to the role of tissue transglutaminase and to selective vulnerability. Journal of Neurochemistry. 1999;72(3):889-899. Not sensitivity or specificity of an identified test. [pmid: 10037459].
Cooper A J, Wang J, Pasternack R, et al. Lysine-rich histone (H1) is a lysyl substrate of tissue transglutaminase: possible involvement of transglutaminase in the formation of nuclear aggregates in (CAG)(n)/Q(n) expansion diseases. Developmental Neuroscience. 2000;22(56):404-417. Not sensitivity or specificity of an identified test. [pmid: 11111157].
Cooper B T, Holmes G K T, Ferguson R. Celiac disease and malignancy. Medicine. 1980;59(4):249-261. Not sensitivity or specificity of an identified test. [pmid: 7392945].
Cooper B T, Holmes G K, Ferguson R, et al. Gluten-sensitive diarrhea without evidence of celiac disease. Gastroenterology. 1980;79(5 Pt 1):801-806. Not sensitivity or specificity of an identified test. [pmid: 7419003].
Cooper D L, Doria R, Salloum E. Primary gastrointestinal lymphomas. Gastroenterologist. 1996;4(1):54-64. Not sensitivity or specificity of an identified test. [pmid: 8689146].
Coppo R. The pathogenetic potential of environmental antigens in IgA nephropathy. American Journal of Kidney Diseases - the Official Journal of the National Kidney Foundation. 1988;12(5):420-424. Not sensitivity or specificity of an identified test. [pmid: 3055968].
Coppo R, Amore A, Roccatello D. Dietary antigens and primary immunoglobulin A nephropathy. Journal of the American Society of Nephrology - Jasn. 1992;2(10 Suppl):S173-S180. Not sensitivity or specificity of an identified test. [pmid: 1600133].
Coppo R, Mazzucco G, Martina G, et al. Gluten-induced experimental IgA glomerulopathy. Lab Invest. 1989;60(4):499-506. Not sensitivity or specificity of an identified test. [pmid: 2709812].
Corazza G R, Gasbarrini G. Coeliac disease in adults. Bailliere's Clinical Gastroenterology. 1995;9(2):329-350. Not sensitivity or specificity of an identified test. [pmid: 7549030].
Corazza G R, Andreani M L, Biagi F, et al. The smaller size of the ‘coeliac iceberg’ in adults. Scandinavian Journal of Gastroenterology. 1997;32(9):917-919. Not sensitivity or specificity of an identified test. [pmid: 9299671].
Corazza G R, Biagi F, Volta U, et al. Autoimmune enteropathy and villous atrophy in adults. Lancet. 1997;350(9071):106-109. Not sensitivity or specificity of an identified test. [pmid: 9228963].
Corazza G R, Brusco G, Andreani M L, et al. Previous misdiagnosis and diagnostic delay in adult celiac sprue. Journal of Clinical Gastroenterology. 1996;22(4):324-325. Not sensitivity or specificity of an identified test. [pmid: 8771434].
Corazza G R, Caletti G C, Lazzari R, et al. Scalloped duodenal folds in childhood celiac disease. Gastrointestinal Endoscopy. 1993;39(4):543-545. Not sensitivity or specificity of an identified test. [pmid: 8365604].
Corazza G R, Falasca A, Strocchi A, et al. Decreased plasma postheparin diamine oxidase levels in celiac disease. Digestive Diseases and Sciences. 1988;33(8):956-961. Not sensitivity or specificity of an identified test. [pmid: 3134178].
Corazza G R, Frazzoni M, Gasbarrini G. Jejunal intraepithelial lymphocytes in coeliac disease: are they increased or decreased?. Gut. 1984;25(2):158-162. Not sensitivity or specificity of an identified test. [pmid: 6693043]. [pmcid: 1432248].
Corazza G R, Frazzoni M, Dixon M F, et al. Quantitative assessment of the mucosal architecture of jejunal biopsy specimens: a comparison between linear measurement, stereology, and computer aided microscopy. Journal of Clinical Pathology. 1985;38(7):765-770. Unable to extract data. [pmid: 3894431]. [pmcid: 499300].
Corazza G R, Frisoni M, Mantovani W, et al. Dermatitis herpetiformis, severity of jejunal lesions and HLA DR7. European Journal of Gastroenterology & Hepatology. 1990;2(5):357-360. Not sensitivity or specificity of an identified test.
Corazza G R, Frisoni M, Treggiari E A, et al. Subclinical celiac sprue. Increasing occurrence and clues to its diagnosis. Journal of Clinical Gastroenterology. 1993;16(1):16-21. Not sensitivity or specificity of an identified test. [pmid: 8421137].
Corazza G R, Ginaldi L, Falasca A, et al. Diamine oxidase plasma activities after treatment with heparin and jejunal morphometry in untreated coeliac disease. Journal of Clinical Pathology. 1989;42(11):1136-1139. Not sensitivity or specificity of an identified test. [pmid: 2511229]. [pmcid: 501968].
Corazza G R, Tabacchi P, Frisoni M, et al. T-lymphocyte subsets in adult coeliac disease. Clinical Science (London, England - 1979). 1983;65(1):89-90. Not sensitivity or specificity of an identified test. [pmid: 6221857].
Corazza G R, Tabacchi P, Frisoni M, et al. DR and non-DR Ia allotypes are associated with susceptibility to coeliac disease. Gut. 1985;26(11):1210-1213. Not sensitivity or specificity of an identified test. [pmid: 3877664]. [pmcid: 1432914].
Corazza G R, Valentini R A, Andreani M L, et al. Subclinical coeliac disease is a frequent cause of iron-deficiency anaemia. Scandinavian Journal of Gastroenterology. 1995;30(2):153-156. Not sensitivity or specificity of an identified test. [pmid: 7732338].
Corazza G, Valentini R A, Frisoni M, et al. Gliadin immune reactivity is associated with overt and latent enteropathy in relatives of celiac patients. Gastroenterology. 1992;103(5):1517-1522. Not sensitivity or specificity of an identified test. [pmid: 1426870].
Cordella-Miele E, Miele L, Mukherjee A B. A novel transglutaminase-mediated post-translational modification of phospholipase A2 dramatically increases its catalytic activity. Journal of Biological Chemistry. 1990;265(28):17180-17188. Not sensitivity or specificity of an identified test. [pmid: 1976627].
Cornell H J. Amino acid composition of peptides remaining after in vitro digestion of a gliadin sub-fraction with duodenal mucosa from patients with coeliac disease. Clin Chim Acta. 1988;176(3):279-290. Not sensitivity or specificity of an identified test. [pmid: 3180479].
Cornell H J, Townley R R. The effect of gliadin peptides on rat-liver lysosomes in relation to the pathogenesis of coeliac disease. Clinica Chimica Acta 1973;International Journal of Clinical Chemistry; 49(2):181–188. Not sensitivity or specificity of an identified test
Corrado F, Magazzu G, Sferlazzas C. Diagnosis of celiac disease in pregnancy and puerperium: Think about it. Acta Obstet Gynecol Scand. 2002;81(2):180-181. Not sensitivity or specificity of an identified test. [pmid: 11942914].
Corrao G, Corazza G R, Andreani M L, et al. Serological screening of coeliac disease: choosing the optimal procedure according to various prevalence values. Gut. 1994;35(6):771-775. Improper control group. [pmid: 8020803]. [pmcid: 1374876].
Costantini V, Zacharski L R, Memoli V A, et al. Fibrinogen deposition without thrombin generation in primary human breast cancer tissue. Cancer Research. 1991;51(1):349-353. Not sensitivity or specificity of an identified test. [pmid: 1846311].
Cottone M, Marrone C, Casa A, et al. Familial occurrence of inflammatory bowel disease in celiac disease. Inflammatory Bowel Dis. 2003;9(5):321-323. Not sensitivity or specificity of an identified test.
Cottone M, Termini A, Oliva L, et al. Mortality and causes of death in celiac disease in a Mediterranean area. Digestive Diseases and Sciences. 1999;44(12):2538-2547. Not sensitivity or specificity of an identified test. [pmid: 10630509].
Coutinho H B, Robalinho T I, Coutinho V B, et al. Immunocytochemistry of mucosal changes in patients infected with the intestinal nematode Strongyloides stercoralis. Journal of Clinical Pathology. 1996;49(9):717-720. Not sensitivity or specificity of an identified test. [pmid: 9038754]. [pmcid: 500719].
Cox A D, Devine D V. Factor XIIIa binding to activated platelets is mediated through activation of glycoprotein IIb-IIIa. Blood. 1994;83(4):1006-1016. Not sensitivity or specificity of an identified test. [pmid: 7906563].
Cox M A, Lewis K O, Cooper B T. Sucrosemia in untreated celiac disease: a potential screening test. Digestive Diseases and Sciences. 1998;43(5):1096-1101. Not sensitivity or specificity of an identified test. [pmid: 9590427].
Crabtree J E, Heatley R V, Trejdosiewicz L K, et al. T lymphocyte stimulation of human small intestinal glycoprotein biosynthesis: effects of anti-CD3 antibody on normal and coeliac mucosa. International Archives of Allergy and Applied Immunology. 1990;93(1):35-40. Not sensitivity or specificity of an identified test. [pmid: 2150837].
Cremata J A, Sorell L, Montesino R, et al. Hypogalactosylation of serum IgG in patients with coeliac disease. Clinical and Experimental Immunology. 2003;133(3):422-429. Not sensitivity or specificity of an identified test. [pmid: 12930370]. [pmcid: 1808795].
Crenn Pascal, Vahedi Kouroche, Lavergne-Slove Anne, et al. Plasma citrulline: A marker of enterocyte mass in villous atrophy-associated small bowel disease. Gastroenterology. 2003;124(5):1210-1219. Not sensitivity or specificity of an identified test. [pmid: 12730862].
Cristallo M, Braga M, Agape D, et al. Nutritional status, function of the small intestine and jejunal morphology after total gastrectomy for carcinoma of the stomach. Surgery, Gynecology & Obstetrics. 1986;163(3):225-230. Not sensitivity or specificity of an identified test. [pmid: 3750177].
Crofton R W, Gvozdanovic S, Gvozdanovic D. Abnormal oral zinc tolerance but normal true absorption of zinc in coeliac disease?. Nutr Res. 1985;5(Suppl 1):S-410. Not sensitivity or specificity of an identified test.
Cronin C, Shanahan F. A significant step in the celiac puzzle. Gastroenterology. 1998;114(6):1339-1341. Not sensitivity or specificity of an identified test. [pmid: 9618654].
Cronin C C, Feighery A, Ferriss J B, et al. High prevalence of celiac disease among patients with insulin-dependent (type I) diabetes mellitus. American Journal of Gastroenterology. 1997;92(12):2210-2212. Not sensitivity or specificity of an identified test. [pmid: 9399754].
Cronin C C, Jackson L M, Feighery C, et al. Coeliac disease and epilepsy. Qjm - Monthly Journal of the Association of Physicians. 1998;91(4):303-308. Not sensitivity or specificity of an identified test. [pmid: 9666954].
Cronin Cornelius C, Shanahan Fergus. Exploring the iceberg--the spectrum of celiac disease. American Journal of Gastroenterology. 2003;98(3):518-520. Not sensitivity or specificity of an identified test. [pmid: 12650779].
Cryan E M, Stevens F M, Skehill R, et al. Immunoglobulins in healthy controls: HLA-B8 and sex differences. Tissue Antigens. 1985;26(4):254-258. Not sensitivity or specificity of an identified test. [pmid: 3878013].
Csizmadia C G D S, Mearin M L, Von Blomberg B M E, et al. An iceberg of childhood coeliac disease in the Netherlands. Lancet. 1999;353(9155):813-814. Not sensitivity or specificity of an identified test. [pmid: 10459972].
Csizmadia C G, Mearin M L, Oren A, et al. Accuracy and cost-effectiveness of a new strategy to screen for celiac disease in children with Down syndrome. Journal of Pediatrics. 2000;137(6):756-761. Improper control group. [pmid: 11113830].
Cuillerier E, Landi B, Cellier C. Is push enteroscopy useful in patients with malabsorption of unclear origin?. American Journal of Gastroenterology. 2001;96(7):2103-2106. Not sensitivity or specificity of an identified test. [pmid: 11467639].
Cummins A G, Thompson F M, Butler R N, et al. Improvement in intestinal permeability precedes morphometric recovery of the small intestine in coeliac disease. Clinical Science (London, England - 1979). 2001;100(4):379-386. Not sensitivity or specificity of an identified test. [pmid: 11256975].
Cunningham-Rundles S, Cunningham-Rundles C, Pollack M S. Response to wheat antigen in in vitro lymphocyte transformation among HLA-B8-positive normal donors. Transplant Proc. 1978;10(4):977-979. Not sensitivity or specificity of an identified test. [pmid: 734750].
Cuoco L, Cammarota G, Jorizzo R A, et al. Link between Helicobacter pylori infection and iron-deficiency anaemia in patients with coeliac disease. Scandinavian Journal of Gastroenterology. 2001;36(12):1284-1288. Not sensitivity or specificity of an identified test. [pmid: 11761018].
Cuoco L, Cammarota G, Tursi A, et al. Disappearance of gastric mucosa-associated lymphoid tissue in coeliac patients after gluten withdrawal. Scandinavian Journal of Gastroenterology. 1998;33(4):401-405. Not sensitivity or specificity of an identified test. [pmid: 9605262].
Cuoco L, Certo M, Jorizzo R A, et al. Prevalence and early diagnosis of coeliac disease in autoimmune thyroid disorders. Italian Journal of Gastroenterology and Hepatology. 1999;31(4):283-287. Not sensitivity or specificity of an identified test. [pmid: 10425571].
Cuomo A, Romano M, Rocco A, et al. Reflux oesophagitis in adult coeliac disease: Beneficial effect of a gluten free diet. Gut. 2003;52(4):514-517. Not sensitivity or specificity of an identified test. [pmid: 12631661]. [pmcid: 1773586].
Cuzzi-Maya T, Sidbury R, Epstein W L, et al. Thrombomodulin expression on dermal cells in normal and psoriatic skin. Archives of Dermatological Research. 1998;290(5):233-239. Not sensitivity or specificity of an identified test. [pmid: 9681673].
Czaja A J. Autoimmune liver disease. Curr Opin Gastroenterol. 1999;15(3):240-248. Not sensitivity or specificity of an identified test. [pmid: 17023951].
Czaja A J, Norman G L. Autoantibodies in the diagnosis and management of liver disease. Journal of Clinical Gastroenterology. 2003;37(4):315-329. Not sensitivity or specificity of an identified test. [pmid: 14506390].
Czaja A J, Santrach P J, Moore S B. HLA-DQ associations in type 1 autoimmune hepatitis. Mayo Clin Proc. 1995;70(12):1154-1160. Not sensitivity or specificity of an identified test. [pmid: 7490916].
D'Agostino L, Ciacci C, Daniele B, et al. Postheparin plasma diamine oxidase in subjects with small bowel mucosal atrophy. Digestive Diseases and Sciences. 1987;32(3):313-317. Not sensitivity or specificity of an identified test. [pmid: 3102190].
D'Agostino L, Daniele B, Pignata S, et al. Postheparin plasma diamine oxidase increases in patients with coeliac disease during gluten free diet. Gut. 1987;28(Suppl):131-134. Not sensitivity or specificity of an identified test. [pmid: 3121454].
D'Agostino L, Daniele B, Pignata S, et al. Postheparin plasma diamine oxidase in subjects with small bowel disease. Diagnostic efficiency of a simplified test. Digestion. 1988;41(1):46-54. Not sensitivity or specificity of an identified test. [pmid: 3144470].
D'Argenio G, Biancone L, Cosenza V, et al. Transglutaminases in Crohn's disease. Gut. 1995;37(5):690-695. Not sensitivity or specificity of an identified test. [pmid: 8549947]. [pmcid: 1382876].
D'Argenio G, Grossman A, Cosenza V, et al. Recombinant factor XIII improves established experimental colitis in rats. Digestive Diseases and Sciences. 2000;45(5):987-997. Not sensitivity or specificity of an identified test. [pmid: 10795765].
D'Argenio G, Sorrentini I, Ciacci C, et al. Human serum transglutaminase and coeliac disease: correlation between serum and mucosal activity in an experimental model of rat small bowel enteropathy. Gut. 1989;30(7):950-954. Not sensitivity or specificity of an identified test. [pmid: 2569434]. [pmcid: 1434281].
Dadabay C Y, Pike L J. Purification and characterization of a cytosolic transglutaminase from a cultured human tumour-cell line. Biochemical Journal. 1989;264(3):679-685. Not sensitivity or specificity of an identified test. [pmid: 2575900]. [pmcid: 1133640].
Dahan S, Slater P E, Cooper M, et al. Coeliac disease in the Rehovot-Ashdod region of Israel: incidence and ethnic distribution. Journal of Epidemiology and Community Health. 1984;38(1):58-60. Not sensitivity or specificity of an identified test. [pmid: 6608573].
Dahele A, Ghosh S. Vitamin B12 deficiency in untreated celiac disease. American Journal of Gastroenterology. 2001;96(3):745-750. Not sensitivity or specificity of an identified test. [pmid: 11280545].
Dahele Anna, Aldhous Marian C, Kingstone Kathleen, et al. Gut mucosal immunity to tissue transglutaminase in untreated celiac disease and other gastrointestinal disorders. Digestive Diseases and Sciences. 2002;47(10):2325-2335. Improper control group. [pmid: 12395906].
Dahlqvist A, Lindberg T, Meeuwisse G, et al. Intestinal dipeptidases and disaccharidases in children with malabsorption. Acta Paediatrica Scandinavica. 1970;59(6):621-630. Not sensitivity or specificity of an identified test. [pmid: 5478216].
Dahlqvist G. Celiac disease and insulin-dependent diabetes mellitus--no proof for a causal association. Acta Paediatr. 1995;84(12):1337-1338. Not sensitivity or specificity of an identified test. [pmid: 8645946].
Dallabrida S M, Falls L A, Farrell D H. Factor XIIIa supports microvascular endothelial cell adhesion and inhibits capillary tube formation in fibrin. Blood. 2000;95(8):2586-2592. Not sensitivity or specificity of an identified test. [pmid: 10753838].
Damoiseaux Jan G M C, Bouten Bas, Linders Annick M L W, et al. Diagnostic value of anti-Saccharomyces cerevisiae and antineutrophil cytoplasmic antibodies for inflammatory bowel disease: high prevalence in patients with celiac disease. Journal of Clinical Immunology. 2002;22(5):281-288. Not sensitivity or specificity of an identified test. [pmid: 12405161].
Damoiseaux J G M C, Tervaert J W C. Celiac disease: the role of (auto)antibody detection in diagnosis and follow-up. Netherlands Journal of Medicine. 2002;60(7):303-304. Not sensitivity or specificity of an identified test. [pmid: 12430584].
Dandalides S M, Carey W D, Petras R, et al. Endoscopic small bowel mucosal biopsy: a controlled trial evaluating forceps size and biopsy location in the diagnosis of normal and abnormal mucosal architecture. Gastrointestinal Endoscopy. 1989;35(3):197-200. Not sensitivity or specificity of an identified test. [pmid: 2668099].
Danielsson L, Stenhammar L, Astrom E. Is gluten challenge necessary for the diagnosis of coeliac disease in young children?. Scandinavian Journal of Gastroenterology. 1990;25(9):957-960. Not sensitivity or specificity of an identified test. [pmid: 2218400].
Dardik R, Shenkman B, Tamarin I, et al. Factor XIII mediates adhesion of platelets to endothelial cells through alpha(v)beta(3) and glycoprotein IIb/IIIa integrins. Thrombosis Research. 2002;105(4):317-323. Not sensitivity or specificity of an identified test. [pmid: 12031826].
Darke C, Winkler S, Guttridge M G, et al. Molecular, serological and population studies of the alleles and products of HLA-B*41. Exp Clin Immunogenet. 1999;16(3):139-149. Not sensitivity or specificity of an identified test. [pmid: 10394052].
Datta M, Shtauvere-Brameus A, Gupta V, et al. Autoimmune diabetes in 26 villages outside Madras. Ann New York Acad Sci. 2002;958(-):285-288. Not sensitivity or specificity of an identified test. [pmid: 12021125].
Daum S, Bauer U, Foss H D, et al. Increased expression of mRNA for matrix metalloproteinases-1 and -3 and tissue inhibitor of metalloproteinases-1 in intestinal biopsy specimens from patients with coeliac disease. Gut. 1999;44(1):17-25. Not sensitivity or specificity of an identified test. [pmid: 9862821]. [pmcid: 1760063].
Daum S, Bauer U, Foss H D et al. Expression of matrix metalloprotease-1 and collagen I mRNA in biopsies from patients with celiac disease. Annals of the New York Academy of Sciences 1998;859254–257. Not sensitivity or specificity of an identified test
Daum S, Weiss D, Hummel M, et al. Frequency of clonal intraepithelial T lymphocyte proliferations in enteropathy-type intestinal T cell lymphoma, coeliac disease, and refractory sprue. Gut. 2001;49(6):804-812. Not sensitivity or specificity of an identified test. [pmid: 11709515]. [pmcid: 1728529].
Dausset J. Biologic role of the HLA system. HLA complex in human biology in the light of associations with disease. Transplantation Proceedings. 1977;9(1):523-529. Not sensitivity or specificity of an identified test. [pmid: 867501].
Dausset J, Hors J. Some contributions of the HL-A complex to the genetics of human diseases. Transplantation Reviews 1975;2244–74. Not sensitivity or specificity of an identified test
David T J, Ajdukiewicz A B. A family study of coeliac disease. J Med Genet. 1975;12(1):79-82. Not sensitivity or specificity of an identified test. [pmid: 1121023].
Davidson A G, Hassall E G. Screening for celiac disease. Cmaj - Canadian Medical Association Journal = Journal De L'association Medicale Canadienne. 1997;157(5):547-548. Not sensitivity or specificity of an identified test.
Davies M L, Taylor E J, Gordon C, et al. Candidate T cell epitopes of the human La/SSB autoantigen. Arthritis Rheum. 2002;46(1):209-214. Not sensitivity or specificity of an identified test. [pmid: 11817592].
Davies P J A, Cornwell M M, Johnson J D. Studies on the effects of dansylcadaverine and related compounds on receptor-mediated endocytosis in cultured cells. Diabetes Care. 1984;7(Suppl 1):35-41. Not sensitivity or specificity of an identified test. [pmid: 6145551].
Davies P J, Chiocca E A, Stein J P. Retinoid--regulated expression of tissue transglutaminase in normal and leukemic myeloid cells. Advances in Experimental Medicine and Biology 1988;23163–71. Not sensitivity or specificity of an identified test
Davies P J, Murtaugh M P, Moore W T, et al. Retinoic acid-induced expression of tissue transglutaminase in human promyelocytic leukemia (HL-60) cells. Journal of Biological Chemistry. 1985;260(8):5166-5174. Not sensitivity or specificity of an identified test. [pmid: 2859286].
Dawood F H, Jabbar A A, Al Mudaris A F, et al. Association of HLA antigens with coeliac disease among Iraqi children. Tissue Antigens. 1981;18(1):35-39. Not sensitivity or specificity of an identified test. [pmid: 6949339].
Dawson D J, Lobley R W, Burrows P C. Lactose digestion by human jejunal biopsies: The relationship between hydrolysis and absorption. Gut. 1986;27(5):521-527. Not sensitivity or specificity of an identified test. [pmid: 3084346]. [pmcid: 1433508].
Dawson D J, Lobley R W, Burrows P C, et al. Changes in jejunal permeability and passive permeation of sugars in intestinal biopsies in coeliac disease and Crohn's disease. Clinical Science (London, England - 1979). 1988;74(4):427-431. Not sensitivity or specificity of an identified test. [pmid: 3128419].
Dawson J, Bryant M G, Bloom S R, et al. Gastrointestinal regulatory peptide storage granule abnormalities in jejunal mucosal diseases. Gut. 1984;25(6):636-643. Not sensitivity or specificity of an identified test. [pmid: 6145662]. [pmcid: 1432371].
Day A S, Cook H B, Whitehead M, et al. Anti-endomysial and anti-gliadin antibodies in screening for coeliac disease in children at greater risk of developing coeliac disease. New Zealand Medical Journal. 2000;113(1119):412-413. Improper control group. [pmid: 11127356].
De Block C E, De Leeuw I, Vertommen J J, et al. Beta-cell, thyroid, gastric, adrenal and coeliac autoimmunity and HLA-DQ types in type 1 diabetes. Clinical and Experimental Immunology. 2001;126(2):236-241. Not sensitivity or specificity of an identified test. [pmid: 11703366]. [pmcid: 1906197].
De Giacomo C, Gianatti A, Negrini R, et al. Lymphocytic gastritis: a positive relationship with celiac disease. Journal of Pediatrics. 1994;124(1):57-62. Not sensitivity or specificity of an identified test. [pmid: 8283376].
de la, Concha E G, Fernandez-Arquero M, et al. Celiac disease and TNF promoter polymorphisms. Human Immunology. 2000;61(5):513-517. Not sensitivity or specificity of an identified test. [pmid: 10773355].
de la, Paz Bettinotti M, Kolek A, et al. Polymorphism of the 5′ flanking region of the HLA-DQA1 gene in coeliac disease. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1993;20(5):399-407. Not sensitivity or specificity of an identified test. [pmid: 9098408].
de Launey W E. Letter: Dermatitis herpetiformis and the enteropathy of celiac disease. Archives of Dermatology. 1974;110(2):301. Not sensitivity or specificity of an identified test. [pmid: 4852749].
de Lecea A, Ribes-Koninckx C, Polanco I et al. Serological screening (antigliadin and antiendomysium antibodies) for non-overt coeliac disease in children of short stature. Acta Paediatrica (Oslo, Norway - 1992).Supplement 1996;41254–55. Improper control group
De Libero G, Rocci M P, Casorati G, et al. T cell receptor heterogeneity in gammadelta T cell clones from intestinal biopsies of patients with celiac disease. Eur J Immunol. 1993;23(2):499-504. Not sensitivity or specificity of an identified test. [pmid: 8436183].
De Martelaere D, Cassiman J J, van Leuven F. Human osteosarcoma derived clonal variants: Stable differences in cell surface composition. Cell Biol Int Rep. 1982;6(5):489-494. Not sensitivity or specificity of an identified test. [pmid: 6124320].
de Pablo R, Vilches C, Moreno M E, et al. Distribution of HLA antigens in Spanish Gypsies: a comparative study. Tissue Antigens. 1992;40(4):187-196. Not sensitivity or specificity of an identified test. [pmid: 1361688].
de Ritis G, Auricchio S, Jones H W, et al. In vitro (organ culture) studies of the toxicity of specific A-gliadin peptides in celiac disease. Gastroenterology. 1988;94(1):41-49. Not sensitivity or specificity of an identified test. [pmid: 3335296].
de Sousa J S, Duarte J P. Letter: Fingerprints in childhood coeliac disease. Archives of Disease in Childhood. 1974;49(1):80. Not sensitivity or specificity of an identified test. [pmid: 4818108].
De Vizia B, Poggi V, Conenna R, et al. Iron absorption and iron deficiency in infants and children with gastrointestinal diseases. Journal of Pediatric Gastroenterology and Nutrition. 1992;14(1):21-26. Not sensitivity or specificity of an identified test. [pmid: 1573507].
De Vos M. Articular diseases and the gut: evidence for a strong relationship between spondylarthropathy and inflammation of the gut in man. Acta Clinica Belgica. 1990;45(1):20-24. Not sensitivity or specificity of an identified test. [pmid: 2161601].
De Vries N, Van Elderen C, Tijssen H, et al. No support for HLA-DQ encoded susceptibility in rheumatoid arthritis. Arthritis Rheum. 1999;42(8):1621-1627. Not sensitivity or specificity of an identified test. [pmid: 10446860].
de Freitas I, Sipahi Aytan, Miranda Damiao, et al. Celiac disease in Brazilian adults. Journal of Clinical Gastroenterology. 2002;34(4):430-434. Not sensitivity or specificity of an identified test. [pmid: 11907355].
De Laurenzi V, Melino G. Gene disruption of tissue transglutaminase. Mol Cell Biol. 2001;21(1):148-155. Not sensitivity or specificity of an identified test. [pmid: 11113189]. [pmcid: 88788].
De Vitis I, Ghirlanda G, Gasbarrini G. Prevalence of coeliac disease in type I diabetes: a multicentre study. Acta Paediatrica (Oslo, Norway - 1992).Supplement 1996;41256–57. Not sensitivity or specificity of an identified test
Dedeoglu Alpaslan, Kubilus James K, Jeitner Thomas M, et al. Therapeutic effects of cystamine in a murine model of Huntington's disease. Journal of Neuroscience - the Official Journal of the Society for Neuroscience. 2002;22(20):8942-8950. Not sensitivity or specificity of an identified test.
Defacque H, Commes T, Contet V, et al. Differentiation of U937 myelomonocytic cell line by all-trans retinoic acid and 1,25-dihydroxyvitamin D3: synergistic effects on tissue transglutaminase. Leukemia - Official Journal of the Leukemia Society of America, Leukemia Research Fund, U.k. 1995;9(10):1762-1767. Not sensitivity or specificity of an identified test. [pmid: 7564522].
deFranchis R, Primignani M, Cipolla M, et al. Small-bowel involvement in dermatitis herpetiformis and in linear-IgA bullous dermatosis. Journal of Clinical Gastroenterology. 1983;5(5):429-436. Not sensitivity or specificity of an identified test. [pmid: 6355270].
Degli-Esposti M A, Abraham L J, McCann V, et al. Ancestral haplotypes reveal the role of the central MHC in the immunogenetics of IDDM. Immunogenetics. 1992;36(6):345-356. Not sensitivity or specificity of an identified test. [pmid: 1356098].
Deininger M H, Grote E, Wickboldt J, et al. Distinct radiochemotherapy protocols differentially influence cellular proliferation and expression of p53 and Bcl-2 in glioblastoma multiforme relapses in vivo. J Neuro-Oncol. 2000;48(2):121-129. Not sensitivity or specificity of an identified test.
Dejmek A, Hjerpe A. Reactivity of six antibodies in effusions of mesothelioma, adenocarcinoma and mesotheliosis: stepwise logistic regression analysis. Cytopathology - Official Journal of the British Society for Clinical Cytology. 2000;11(1):8-17. Not sensitivity or specificity of an identified test. [pmid: 10714371].
Del Rosario M A, Fitzgerald J F, Chong S K, et al. Further studies of anti-endomysium and anti-gliadin antibodies in patients with suspected celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1998;27(2):191-195. Improper control group. [pmid: 9702652].
Deller D J, Murrell T G, Blowes R. Jejunal biopsy in malignant disease. Australasian Annals of Medicine. 1967;16(3):236-241. Not sensitivity or specificity of an identified test. [pmid: 6056612].
Delprato G R, Petit-Phar M, Maadi A B, et al. IgA antigliadin antibodies as a possible marker for IgA mesangial glomerulonephritis in adults with primary glomerulonephritis. New Engl J Med. 1989;320(19):1283-1284. Not sensitivity or specificity of an identified test. [pmid: 2710210].
DeMarchi M, Borelli I, Olivetti E, et al. Two HLA-D and DR alleles are associated with coeliac disease. Tissue Antigens. 1979;14(4):309-316. Not sensitivity or specificity of an identified test. [pmid: 94703].
DeMarchi M, Carbonara A, Ansaldi N, et al. HLA-DR3 and DR7 in coeliac disease: immunogenetic and clinical aspects. Gut. 1983;24(8):706-712. Not sensitivity or specificity of an identified test. [pmid: 6603391]. [pmcid: 1420226].
Demediuk B. Investigating a patient with a positive test for antigliadin antibodies. Med Today. 2001;2(9):87. Not sensitivity or specificity of an identified test.
Demir H, Yuce A, Kocak N, et al. Celiac disease in Turkish children: presentation of 104 cases. Pediatrics International - Official Journal of the Japan Pediatric Society. 2000;42(5):483-487. Improper control group. [pmid: 11059535].
Dempfle C E, Harenberg J, Hochreuter K, et al. Microtiter assay for measurement of factor XIII activity in plasma. Journal of Laboratory and Clinical Medicine. 1992;119(5):522-528. Not sensitivity or specificity of an identified test. [pmid: 1349910].
Deng Lei, Shipley Gregory L, Loose-Mitchell David S, et al. Coordinate regulation of the production and signaling of retinoic acid by estrogen in the human endometrium. Journal of Clinical Endocrinology and Metabolism. 2003;88(5):2157-2163. Not sensitivity or specificity of an identified test. [pmid: 12727970].
Dennis N R, Stokes C R. Risk of coeliac disease in children of patients and effect of HLA genotype. Journal of Medical Genetics. 1978;15(1):20-22. Not sensitivity or specificity of an identified test. [pmid: 633317].
Deprez Pierre H, Sempoux Christine, De Saeger, et al. Expression of cholecystokinin in the duodenum of patients with coeliac disease: respective role of atrophy and lymphocytic infiltration. Clinical Science (London, England - 1979). 2002;103(2):171-177. Not sensitivity or specificity of an identified test. [pmid: 12149109].
DerSimonian H, Sugita M, Glass D N, et al. Clonal Valpha12.1sup + T cell expansions in the peripheral blood of rheumatoid arthritis patients. J Exp Med. 1993;177(6):1623-1631. Not sensitivity or specificity of an identified test. [pmid: 8496681].
Desai H G, Chitre A V, Jeejeebhoy K N. Lactose loading. A simple test for detecting intestinal lactase. Evaluation of different methods. Gastroenterologia. 1967;108(4):177-188. Not sensitivity or specificity of an identified test. [pmid: 6077152].
Desjeux J F, Sandler L, Sassier P, et al. Acquired and congenital disorders of intestinal transport of D. glucose in children. Revue Europeenne D'etudes Cliniques Et Biologiques. European Journal of Clinical and Biological Research. 1971;16(4):364-366. Not sensitivity or specificity of an identified test. [pmid: 5564550].
Desombere I, Van der, Wielen M, et al. Immune response of HLA DQ2 positive subjects, vaccinated with HBsAg/AS04, a hepatitis B vaccine with a novel adjuvant. Vaccine. 2002;20(1920):2597-2602. Not sensitivity or specificity of an identified test. [pmid: 12057618].
Devery J M, La Brooy J T, Krillis S, et al. Anti-gliadin antibody specificity for gluten-derived peptides toxic to coeliac patients. Clinical and Experimental Immunology. 1989;76(3):384-390. Not sensitivity or specificity of an identified test. [pmid: 2752594]. [pmcid: 1541896].
Devi Rampertab S, Fleischauer A, Neugut A I, et al. Risk of duodenal adenoma in celiac disease. Scandinavian Journal of Gastroenterology. 2003;38(8):831-833. Not sensitivity or specificity of an identified test. [pmid: 12940435].
Devine D V. Novel markers for the detection of platelet activation. Transfusion Medicine Reviews. 1990;4(2):115-120. Not sensitivity or specificity of an identified test. [pmid: 1724946].
Devine P L, Birrell G W, Golder J P, et al. Screening and monitoring coeliac disease: multicentre trial of a new serum antibody test kit. Disease Markers. 1994;12(1):71-80. Improper control group. [pmid: 7842632].
Dewar D, Pereira S P, Ciclitira P J. The pathogenesis of coeliac disease. Int J Biochem Cell Biol. 2004;36(1):17-24. Not sensitivity or specificity of an identified test. [pmid: 14592529].
Dezi R, Niveloni S, Sugai E, et al. Gluten sensitivity in the rectal mucosa of first-degree relatives of celiac disease patients. American Journal of Gastroenterology. 1997;92(8):1326-1330. Not sensitivity or specificity of an identified test. [pmid: 9260799].
Dhar A, Goenka M K. Endomysial antibody and celiac disease. Indian Journal of Gastroenterology - Official Journal of the Indian Society of Gastroenterology. 1993;12(4):157-158. Not sensitivity or specificity of an identified test. [pmid: 8270300].
Dhesi I, Marsh M N, Kelly C, et al. Morphometric analysis of small intestinal mucosa. II. Determination of lamina propria volumes; plasma cell and neutrophil populations within control and coeliac disease mucosae. Virchows Archiv. A, Pathological Anatomy and Histopathology. 1984;403(2):173-180. Not sensitivity or specificity of an identified test.
Di Mario U, Anastasi E, Mariani P, et al. Diabetes-related autoantibodies do appear in children with coeliac disease. Acta Paediatrica (Oslo, Norway - 1992). 1992;81(8):593-597. Not sensitivity or specificity of an identified test. [pmid: 1392382].
Di Sabatino A, Bertrandi E, Casadei Maldini M, et al. Phenotyping of peripheral blood lymphocytes in adult coeliac disease. Immunology. 1998;95(4):572-576. Not sensitivity or specificity of an identified test. [pmid: 9893047]. [pmcid: 1364354].
Di Sabatino A, Ciccocioppo R, D'Alo S, et al. Intraepithelial and lamina propria lymphocytes show distinct patterns of apoptosis whereas both populations are active in Fas based cytotoxicity in coeliac disease. Gut. 2001;49(3):380-386. Not sensitivity or specificity of an identified test. [pmid: 11511560]. [pmcid: 1728419].
Di Stefano M, Jorizzo R A, Veneto G, et al. Bone mass and metabolism in dermatitis herpetiformis. Digestive Diseases and Sciences. 1999;44(10):2139-2143. Not sensitivity or specificity of an identified test. [pmid: 10548369].
Diamanti A, Maino C, Niveloni S, et al. Characterization of gastric mucosal lesions in patients with celiac disease: a prospective controlled study. American Journal of Gastroenterology. 1999;94(5):1313-1319. Not sensitivity or specificity of an identified test. [pmid: 10235212].
Dias J, Unsworth D J, Walker-Smith J A. Antigliadin and antireticulin antibodies in screening for coeliac disease. Lancet. 1987;2(8551):157-158. Not sensitivity or specificity of an identified test. [pmid: 2885617].
Dickey W. Diagnosis of coeliac disease at open-access endoscopy. Scandinavian Journal of Gastroenterology. 1998;33(6):612-615. Not sensitivity or specificity of an identified test. [pmid: 9669633].
Dickey W. Endoscopy, serology and histology in the diagnosis of coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(3):172-174. Not sensitivity or specificity of an identified test. [pmid: 12118945].
Dickey W. Epilepsy, cerebral calcifications, and coeliac disease. Lancet. 1994;344(8937):1585-1586. Not sensitivity or specificity of an identified test. [pmid: 7983988].
Dickey W, Hughes D. Disappointing sensitivity of endoscopic markers for villous atrophy in a high-risk population: implications for celiac disease diagnosis during routine endoscopy. American Journal of Gastroenterology. 2001;96(7):2126-2128. Not sensitivity or specificity of an identified test. [pmid: 11467643].
Dickey W, Hughes D. Prevalence of celiac disease and its endoscopic markers among patients having routine upper gastrointestinal endoscopy. American Journal of Gastroenterology. 1999;94(8):2182-2186. Not sensitivity or specificity of an identified test. [pmid: 10445547].
Dickey W, McConnell J B. How many hospital visits does it take before celiac sprue is diagnosed?. Journal of Clinical Gastroenterology. 1996;23(1):21-23. Not sensitivity or specificity of an identified test. [pmid: 8835909].
Dickey W, Hughes D F, McMillan S A. Disappearance of endomysial antibodies in treated celiac disease does not indicate histological recovery. American Journal of Gastroenterology. 2000;95(3):712-714. Not sensitivity or specificity of an identified test. [pmid: 10710062].
Dickey W, Hughes D F, McMillan S A. Reliance on serum endomysial antibody testing underestimates the true prevalence of coeliac disease by one fifth. Scandinavian Journal of Gastroenterology. 2000;35(2):181-183. Unable to extract data. [pmid: 10720117].
Dickey W, Kenny B D, McMillan S A, et al. Gastric as well as duodenal biopsies may be useful in the investigation of iron deficiency anaemia. Scandinavian Journal of Gastroenterology. 1997;32(5):469-472. Not sensitivity or specificity of an identified test. [pmid: 9175209].
Dickey W, McMillan S A, Callender M E. High prevalence of celiac sprue among patients with primary biliary cirrhosis. Journal of Clinical Gastroenterology. 1997;25(1):328-329. Not sensitivity or specificity of an identified test. [pmid: 9412913].
Dickey W, McMillan S A, Hughes D F. Identification of coeliac disease in primary care. Scandinavian Journal of Gastroenterology. 1998;33(5):491-493. Not sensitivity or specificity of an identified test. [pmid: 9648987].
Dickey W, McMillan S A, Bharucha C, et al. Antigliadin antibodies in blood donors in Northern Ireland. European Journal of Gastroenterology & Hepatology. 1992;4(9):739-741. Not sensitivity or specificity of an identified test.
Dickey W, McMillan S A, McCrum E E, et al. Association between serum levels of total IgA and IgA class endomysial and antigliadin antibodies: implications for coeliac disease screening. European Journal of Gastroenterology & Hepatology. 1997;9(6):559-562. Improper control group. [pmid: 9222726].
Dickey W, Stewart F, Nelson J, et al. Screening for coeliac disease as a possible maternal risk factor for neural tube defect. Clinical Genetics. 1996;49(2):107-108. Not sensitivity or specificity of an identified test. [pmid: 8740924].
Dickey William. Low serum vitamin B12 is common in coeliac disease and is not due to autoimmune gastritis. European Journal of Gastroenterology & Hepatology. 2002;14(4):425-427. Not sensitivity or specificity of an identified test. [pmid: 11943958].
Dieterich W, Ehnis T, Bauer M, et al. Identification of tissue transglutaminase as the autoantigen of celiac disease. Nature Medicine. 1997;3(7):797-801. Not sensitivity or specificity of an identified test. [pmid: 9212111].
Dieterich W, Esslinger B, Schuppan D. Pathomechanisms in celiac disease. Int Arch Allergy Immunol. 2003;132(2):98-108. Not sensitivity or specificity of an identified test. [pmid: 14600421].
Dieterich W, Laag E, Bruckner-Tuderman L, et al. Antibodies to tissue transglutaminase as serologic markers in patients with dermatitis herpetiformis. Journal of Investigative Dermatology. 1999;113(1):133-136. Not sensitivity or specificity of an identified test. [pmid: 10417632].
Dieterich W, Laag E, Schopper H, et al. Autoantibodies to tissue transglutaminase as predictors of celiac disease. Gastroenterology. 1998;115(6):1317-1321. Improper control group. [pmid: 9834256].
Dieterich W, Storch W B, Schuppan D. Serum antibodies in celiac disease. Clinical Laboratory. 2000;46(78):361-364. Review article. [pmid: 10934583].
Dieterich W, Trapp D, Esslinger B, et al. Autoantibodies of patients with coeliac disease are insufficient to block tissue transglutaminase activity. Gut. 2003;52(11):1562-1566. Not sensitivity or specificity of an identified test. [pmid: 14570723]. [pmcid: 1773855].
Dieye A, Diaw M L, Rogier C, et al. HLA-A, -B, -C, -DR, -DQ typing in a population group of Senegal: Distribution of HLA antigens and HLA-DRB 1(*)13 and DRB 1(*)11 subtyping by PCR using sequence-specific primers (PCR-SSP). Tissue Antigens. 1996;47(3):194-199. Not sensitivity or specificity of an identified test. [pmid: 8740768].
Dinari G, Rosenbach Y, Marcus H, et al. IgA antigliadin antibodies in childhood celiac disease. Israel Journal of Medical Sciences. 1988;24(6):286-290. Serology <1990. [pmid: 3403224].
Dinari G, Zahavi I, Marcus H, et al. Placental ferritin in coeliac disease: relation to clinical stage, origin, and possible role in the pathogenesis of malignancy. Gut. 1991;32(9):999-1003. Not sensitivity or specificity of an identified test. [pmid: 1916505]. [pmcid: 1379037].
Dissanayake A S, Truelove S C, Whitehead R. Jejunal mucosal recovery in coeliac disease in relation to the degree of adherence to a gluten-free diet. Quarterly Journal of Medicine. 1974;43(170):161-185. Not sensitivity or specificity of an identified test. [pmid: 4604652].
Dissanayake A S, Truelove S C, Whitehead R. Lack of harmful effect of oats on small-intestinal mucosa in coeliac disease. British Medical Journal. 1974;4(5938):189-191. Not sensitivity or specificity of an identified test. [pmid: 4417208]. [pmcid: 1612349].
Djilali-Saiah I, Benini V, Schmitz J, et al. Absence of primary association between DM gene polymorphism and insulin-dependent diabetes mellitus or celiac disease. Human Immunology. 1996;49(1):22-27. Not sensitivity or specificity of an identified test. [pmid: 8839772].
Djilali-Saiah I, Caillat-Zucman S, Schmitz J, et al. Polymorphism of antigen processing (TAP, LMP) and HLA class II genes in celiac disease. Human Immunology. 1994;40(1):8-16. Improper control group. [pmid: 8045794].
Djilali-Saiah I, Schmitz J, Harfouch-Hammoud E, et al. CTLA-4 gene polymorphism is associated with predisposition to coeliac disease. Gut. 1998;43(2):187-189. Improper control group. [pmid: 10189842]. [pmcid: 1727221].
Djoulah S, Khalil I, Beressi J P, et al. The HLA-DRB1*0405 haplotype is most strongly associated with IDDM in Algerians. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1992;19(6):381-389. Not sensitivity or specificity of an identified test. [pmid: 1477090].
Dobbins W O, Tomasini J T, Rollins E L. Electron and light microscopic identification of the mast cell of the gastrointestinal tract. Gastroenterology. 1969;56(2):268-279. Not sensitivity or specificity of an identified test. [pmid: 5764594].
Dobru D, Pascu O, Tant cedil, et al. The prevalence of coeliac disease at endoscopy units in Romania: Routine biopsies during gastroscopy are mandatory (A multicentre study). Rom J Gastroenterol. 2003;12(2):97-100. Not sensitivity or specificity of an identified test. [pmid: 12853994].
Dohan F C. Schizophrenia, celiac disease, gluten antibodies, and the importance of beta. Biological Psychiatry. 1981;16(11):1115-1117. Not sensitivity or specificity of an identified test. [pmid: 7349623].
Doherty M, Barry R E. Gluten-induced mucosal changes in subjects without overt small-bowel disease. Lancet. 1981;1(8219):517-520. Not sensitivity or specificity of an identified test. [pmid: 6111631].
Dollberg L, Gurevitz M, Freier S. Gastrointestinal mast cells in health, and in coeliac disease and other conditions. Arch Dis Child. 1980;55(9):702-705. Not sensitivity or specificity of an identified test. [pmid: 7436534].
Dolly J O, Fottrell P F. Multiple forms of dipeptidases in normal human intestinal mucosa and in mucosa from children with coeliac disease. Clinica Chimica Acta 1969;International Journal of Clinical Chemistry; 26(3):555–558. Not sensitivity or specificity of an identified test
Dolly J O, Dillon A, Duffy M J et al. Further studies on multiple forms of peptidases in mammalian tissues including intestinal mucosa from children with treated and untreated coeliac disease. Clinica Chimica Acta 1971;International Journal of Clinical Chemistry; 31(1):55–62. Not sensitivity or specificity of an identified test
Dolynchuk K N, Pettigrew N M. Transglutaminase levels in Dupuytren's disease. Journal of Hand Surgery. 1991;16(5):787-790. Not sensitivity or specificity of an identified test. [pmid: 1682354].
Dolynchuk K N, Ziesmann M, Serletti J M. Topical putrescine (Fibrostat) in treatment of hypertrophic scars: phase II study. Plastic and Reconstructive Surgery. 1996;97(1):117-123. Not sensitivity or specificity of an identified test. [pmid: 8532768].
Domenico Sebastiani G, Minisola G, Galeazzi M. HLA class II alleles and genetic predisposition to the antiphospholipid syndrome. Autoimmun Rev. 2003;2(6):387-394. Not sensitivity or specificity of an identified test. [pmid: 14550881].
Domschke S, Bloom S R, Adrian T E, et al. Abundance of VIP in duodenal mucosa of coeliacs and duodenal ulcer patients. Peptides. 1984;5(2):411-413. Not sensitivity or specificity of an identified test. [pmid: 6473164].
Domschke S, Bloom S R, Adrian T E et al. Coeliac sprue: abnormalities of the hormone profile of gastroduodenal mucosa. Scandinavian Journal of Gastroenterology.Supplement 1989;16786–89. Not sensitivity or specificity of an identified test
Doniach S. The impact of intestinal biopsy on gastroenterology. Gastroenterology 1968;54(4):SupplNot sensitivity or specificity of an identified test
Donner H, Seidl C, Braun J, et al. CTLA4 gene haplotypes cannot protect from IDDM in the presence of high-risk HLA DQ8 or DQ2 alleles in German families. Diabetes. 1998;47(7):1158-1160. Not sensitivity or specificity of an identified test. [pmid: 9648843].
Donohoue P A, Guethlein L, Collins M M, et al. The HLA-A3,Cw6,B47,DR7 extended haplotypes in salt losing 21-hydroxylase deficiency and in the Old Order Amish: Identical class I antigens and class II alleles with at least two crossover sites in the class III region. Tissue Antigens. 1995;46(3 I):163-172. Not sensitivity or specificity of an identified test. [pmid: 8525475].
Douglas A P, Crabbe P A, Hobbs J R. Immunochemical studies on the serum, intestinal secretions and intestinal mucosa in patients with adult celiac disease and other forms of the celiac syndrome. Gastroenterology. 1970;59(3):414-425. Not sensitivity or specificity of an identified test. [pmid: 4195762].
Douthwaite J A, Johnson T S, Haylor J L, et al. Effects of transforming growth factor-beta1 on renal extracellular matrix components and their regulating proteins. Journal of the American Society of Nephrology - Jasn. 1999;10(10):2109-2119. Not sensitivity or specificity of an identified test. [pmid: 10505691].
Douvin C, Simon D, Charles M-A, et al. Hepatitis B vaccination in diabetic patients: Randomized trial comparing recombinant vaccines containing and not containing pre-S2 antigen. Diabetes Care. 1997;20(2):148-151. Not sensitivity or specificity of an identified test. [pmid: 9118762].
Drago S, Di Pierro M, Catassi C, et al. Recent developments in the pathogenesis, diagnosis and treatment of celiac disease. Expert Opin Ther Pat. 2002;12(1):45-51. Not sensitivity or specificity of an identified test.
Drossman D A. Irritable bowel syndrome: how far do you go in the workup?. Gastroenterology. 2001;121(6):1512-1515. Not sensitivity or specificity of an identified test. [pmid: 11729133].
Drover S, Karr R W, Fu X T, et al. Analysis of monoclonal antibodies specific for unique and shared determinants on HLA-DR4 molecules. Human Immunology. 1994;40(1):51-60. Not sensitivity or specificity of an identified test. [pmid: 7519185].
Drukker A, Goldstein R, Maeir D M, et al. Disaccharidase activity in the rectal mucosa. Israel Journal of Medical Sciences. 1972;8(4):502-507. Not sensitivity or specificity of an identified test. [pmid: 5034801].
Drut R, Rua E C. The histopathology of pediatric celiac disease: order must prevail out of chaos. International Journal of Surgical Pathology. 2001;9(4):261-264. Not sensitivity or specificity of an identified test. [pmid: 12574840].
Duggan J M. Recent developments in our understanding of adult coeliac disease. Medical Journal of Australia. 1997;166(6):312-315. Not sensitivity or specificity of an identified test. [pmid: 9087190].
Dugoujon J M, Cambon-Thomsen A. Immunoglobulin allotypes (GM and KM) and their interactions with HLA antigens in autoimmune diseases: a review. Autoimmunity. 1995;22(4):245-260. Not sensitivity or specificity of an identified test. [pmid: 8781716].
Dumic M, Mardesic D, Plavsic V, et al. Coincidence of pseudohypoaldosteronism with gluten-enteropathy. Journal of Endocrinological Investigation. 1984;7(4):395-398. Not sensitivity or specificity of an identified test. [pmid: 6389661].
Duncan A, Park R P, Lee F D, et al. A retrospective assessment of the clinical value of jejunal disaccharidase analysis. Scandinavian Journal of Gastroenterology. 1994;29(12):1111-1116. Not sensitivity or specificity of an identified test. [pmid: 7886399].
Dutz W, Asvadi S, Sadri S, et al. Intestinal lymphoma and sprue: a systematic approach. Gut. 1971;12(10):804-810. Not sensitivity or specificity of an identified test. [pmid: 4941685]. [pmcid: 1411879].
Duvic M, Nelson D C, Annarella M, et al. Keratinocyte transglutaminase expression varies in squamous cell carcinomas. Journal of Investigative Dermatology. 1994;102(4):462-469. Not sensitivity or specificity of an identified test. [pmid: 7908683].
Dvorcakova M, Macejova D, Pallet V, et al. Transglutamines and endocrine system (minireview). Endocrine Regulations. 2002;36(1):31-36. Not sensitivity or specificity of an identified test. [pmid: 11971749].
Dwinell M B, Kagnoff M F. Mucosal immunity. Curr Opin Gastroenterol. 1999;15(1):33-38. Not sensitivity or specificity of an identified test. [pmid: 17023915].
Dyduch A, Karczewska K, Grzybek H, et al. Transmission electron microscopy of microvilli of intestinal epithelial cells in celiac disease in remission and transient gluten enteropathy in children after a gluten-free diet. Journal of Pediatric Gastroenterology and Nutrition. 1993;16(3):269-272. Not sensitivity or specificity of an identified test. [pmid: 8492254].
Eade O E, Lloyd R S, Lang C, et al. IgA and IgG reticulin antibodies in coeliac and non-coeliac patients. Gut. 1977;18(12):991-993. Not sensitivity or specificity of an identified test. [pmid: 342356]. [pmcid: 1411833].
Eckert R L, Welter J F. Epidermal keratinocytes - genes and their regulation. Cell Death Differ. 1996;3(4):373-383. Not sensitivity or specificity of an identified test. [pmid: 17180107].
Ectors N. Infectious disorders of the duodenum: MALADIES INFECTIEUSES DU DUODENUM. Acta Endosc. 2002;32(2):133-156. Not sensitivity or specificity of an identified test.
Egan C A, O'Loughlin S, Gormally S, et al. Dermatitis Herpetiformis: a review of fifty-four patients. Irish Journal of Medical Science. 1997;166(4):241-244. Not sensitivity or specificity of an identified test. [pmid: 9394075].
Egyud L G, Lipinski B. Significance of fibrin formation and dissolution in the pathogenesis and treatment of cancer. Medical Hypotheses. 1991;36(4):336-340. Not sensitivity or specificity of an identified test. [pmid: 1687326].
Ehrmann Jiri, Kolek Antonin, Kod'ousek Rostislav, et al. Immunohistochemical study of the apoptotic mechanisms in the intestinal mucosa during children's coeliac disease. Virchows Archiv - an International Journal of Pathology. 2003;442(5):453-461. Not sensitivity or specificity of an identified test. [pmid: 12698366].
Eichler I, Frisch H, Granditsch G. Growth failure and insulin-like growth factor (IGF-I) in childhood celiac disease. Klinische Wochenschrift. 1991;69(18):825-829. Not sensitivity or specificity of an identified test. [pmid: 1770750].
Eiermann T H, Vejbaesya S, Prestel H, et al. Association and linkage of human leukocyte antigens with psoriasis - Revisited. Infusther Transfusionsmed. 2002;29(6):326-330. Not sensitivity or specificity of an identified test.
Eiras P, Roldan E, Camarero C, et al. Flow cytometry description of a novel CD3-/CD7+ intraepithelial lymphocyte subset in human duodenal biopsies: potential diagnostic value in coeliac disease. Cytometry - the Journal of the Society for Analytical Cytology. 1998;34(2):95-102. Not sensitivity or specificity of an identified test. [pmid: 9579607].
Ejderhamn J, Samuelson K, Strandvik B. Serum primary bile acids in the course of celiac disease in children. Journal of Pediatric Gastroenterology and Nutrition. 1992;14(4):443-449. Not sensitivity or specificity of an identified test. [pmid: 1517948].
Ek J, Albrechtsen D, Solheim B G, et al. Strong association between the HLA-Dw3-related B cell alloantigen -DRw3 and coeliac disease. Scandinavian Journal of Gastroenterology. 1978;13(2):229-233. Not sensitivity or specificity of an identified test. [pmid: 76332].
el Alaoui S, Legastelois S, Roch A M, et al. Transglutaminase activity and N epsilon (gamma glutamyl) lysine isopeptide levels during cell growth: an enzymic and immunological study. International Journal of Cancer. Journal International Du Cancer. 1991;48(2):221-226. Not sensitivity or specificity of an identified test. [pmid: 1673452].
El Gabalawy H S, Goldbach-Mansky R, Smith D, et al. Association of HLA alleles and clinical features in patients with synovitis of recent onset. Arthritis Rheum. 1999;42(8):1696-1705. Not sensitivity or specificity of an identified test. [pmid: 10446870].
el Salhy M. The nature and implication of intestinal endocrine cell changes in coeliac disease. Histology and Histopathology. 1998;13(4):1069-1075. Not sensitivity or specificity of an identified test. [pmid: 9810503].
Elewaut A, Dacremont G, Robberecht E et al. IgA isotyping of antigliadin antibodies. A possible clue for a less invasive diagnosis of coeliac disease. Clinica Chimica Acta 1989;International Journal of Clinical Chemistry; 183(3):285–294. Serology <1990
Elia C, Carneiro A J, Carvalho A T P, et al. Small intestinal morphology in dermatitis herpetiformis: Experience of the Federal University Hospital of Rio de Janeiro, Brazil. An Bras Dermatol. 1998;73(2):87-90. Not sensitivity or specificity of an identified test.
Eliakim R, Heyman S, Kornberg A. Celiac disease and keratoconjunctivitis. Occurrence with thrombocytopenic purpura. Archives of Internal Medicine 1982;142(5):1037. Not sensitivity or specificity of an identified test.
Ellis A. The genetic epidemiology of coeliac disease. Genetic Epidemiology.Supplement 1986;1267–269. Not sensitivity or specificity of an identified test
Ellis A, Taylor C J, Dillon-Remmy M, et al. HLA-DR typing in coeliac disease: evidence for genetic heterogeneity. British Medical Journal (Clinical Research Ed.). 1984;289(6458):1571-1573. Not sensitivity or specificity of an identified test. [pmid: 6439322]. [pmcid: 1443876].
Ellis H J, Ciclitira P J. In vivo gluten challenge in celiac disease. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 2001;15(4):243-247. Not sensitivity or specificity of an identified test. [pmid: 11331926].
Ellis H J, Pollock E L, Engel W, et al. Investigation of the putative immunodominant T cell epitopes in coeliac disease. Gut. 2003;52(2):212-217. Not sensitivity or specificity of an identified test. [pmid: 14633945]. [pmcid: 1774960].
Elmes M E, Jones J G, Stanton M R. Changes in the Paneth cell population of human small intestine assessed by image analysis of the secretory granule area. Journal of Clinical Pathology. 1983;36(8):867-872. Not sensitivity or specificity of an identified test. [pmid: 6875016]. [pmcid: 498414].
Elms M J, Bunce I H, Bundesen P G, et al. Rapid detection of cross-linked fibrin degradation products in plasma using monoclonal antibody-coated latex particles. American Journal of Clinical Pathology. 1986;85(3):360-364. Not sensitivity or specificity of an identified test. [pmid: 2875646].
Elsasser H P, MacDonald R, Dienst M, et al. Characterization of a transglutaminase expressed in human pancreatic adenocarcinoma cells. European Journal of Cell Biology. 1993;61(2):321-328. Not sensitivity or specificity of an identified test. [pmid: 7901019].
Enderlin V, Alfos S, Pallet V, et al. Aging decreases the abundance of retinoic acid (RAR) and triiodothyronine (TR) nuclear receptor mRNA in rat brain: Effect of the administration of retinoids. Febs Lett. 1997;412(3):629-632. Not sensitivity or specificity of an identified test. [pmid: 9276480].
Enderlin V, Pallet V, Alfos S, et al. Age-related decreases in mRNA for brain nuclear receptors and target genes are reversed by retinoic acid treatment. Neurosci Lett. 1997;229(2):125-129. Not sensitivity or specificity of an identified test. [pmid: 9223607].
Engstrom J, Hellstrom K. Microflora of the small intestine and the incidence of liver disease, steatorrhoea, and indicanuria in patients subjected to partial gastrectomy. Acta Chirurgica Scandinavica. 1973;139(6):539-545. Not sensitivity or specificity of an identified test. [pmid: 4753104].
Engstrom J, Hellstrom K, Lundh G, et al. Microflora of small intestine, incidence of steatorrhoea and indicanuria before and after conversion of billroth II to billroth I type of gastric resection. Acta Chirurgica Scandinavica. 1973;139(6):546-550. Not sensitivity or specificity of an identified test. [pmid: 4753104].
Engstrom P E, Sundin U, Lavo B, et al. Class and subclass-associated specificity differences of anti-gliadin antibodies from mucosa and serum. Immunology. 1992;77(4):604-608. Not sensitivity or specificity of an identified test. [pmid: 1493932]. [pmcid: 1421649].
Ensari A, Marsh M N, Loft D E, et al. Morphometric analysis of intestinal mucosa. V. Quantitative histological and immunocytochemical studies of rectal mucosae in gluten sensitivity. Gut. 1993;34(9):1225-1229. Not sensitivity or specificity of an identified test. [pmid: 8406159]. [pmcid: 1375459].
Ensari A, Marsh M N, Morgan S, et al. Diagnosing coeliac disease by rectal gluten challenge: a prospective study based on immunopathology, computerized image analysis and logistic regression analysis. Clinical Science (London, England - 1979). 2001;101(2):199-207. Not sensitivity or specificity of an identified test. [pmid: 11473497].
Eriksson M-O, Hagforsen E, Lundin I P, et al. Palmoplantar pustulosis: A clinical and immunohistological study. Br J Dermatol. 1998;138(3):390-398. Not sensitivity or specificity of an identified test. [pmid: 9580788].
Erkan T, Kutlu T, Yilmaz E, et al. Human leukocyte antigens in Turkish pediatric celiac patients. Turkish Journal of Pediatrics. 1999;41(2):181-188. Improper control group. [pmid: 10770656].
Ermacora E, Prampolini L, Tribbia G. Long-term follow-up of dermatitis herpetiformis in children. J Am Acad Dermatol. 1986;15(1):24-30. Not sensitivity or specificity of an identified test. [pmid: 3722506].
Ertem D, Tuney D, Baloglu H, et al. Superior mesenteric artery blood flow in children with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1998;26(2):140-145. Not sensitivity or specificity of an identified test. [pmid: 9481627].
Esposito C, Lombardi M L, Ruocco V, et al. Implication of tissue transglutaminase and desmoplakin in cell adhesion mechanism in human epidermis. Molecular and Cellular Biochemistry. 2000;206(12):57-65. Not sensitivity or specificity of an identified test. [pmid: 10839195].
Esposito C, Paparo F, Caputo I, et al. Anti-tissue transglutaminase antibodies from coeliac patients inhibit transglutaminase activity both in vitro and in situ. Gut. 2002;51(2):177-181. Not sensitivity or specificity of an identified test. [pmid: 12117875]. [pmcid: 1773330].
Esposito Carla, Marra Monica, Giuberti Gaia, et al. Ubiquitination of tissue transglutaminase is modulated by interferon alpha in human lung cancer cells. Biochemical Journal. 2003;370(Pt 1):205-212. Not sensitivity or specificity of an identified test. [pmid: 12401132]. [pmcid: 1223138].
Esposito Carla, Paparo Francesco, Caputo Ivana, et al. Expression and enzymatic activity of small intestinal tissue transglutaminase in celiac disease. American Journal of Gastroenterology. 2003;98(8):1813-1820. Not sensitivity or specificity of an identified test. [pmid: 12907337].
Esterre P, Risteli L, Ricard-Blum S. Immunohistochemical study of type I collagen turn-over and of matrix metalloproteinases in chromoblastomycosis before and after treatment by terbinafine. Pathology, Research and Practice. 1998;194(12):847-853. Not sensitivity or specificity of an identified test. [pmid: 9894250].
Eterman K P, Nefkens M J J, Van Der, et al. Failure to detect specific gluten antigens associated with the immune aggregates in the skin in dermatitis herpetiformis. Arch Dermatol Res. 1977;260(3):247-252. Not sensitivity or specificity of an identified test. [pmid: 74984].
Euler A R, Ament M E. Celiac sprue and Crohn's disease: an association causing severe growth retardation. Gastroenterology. 1977;72(4 $U1):729-731. Not sensitivity or specificity of an identified test. [pmid: 870375].
Evans D J, Patey A L. Chemistry of wheat proteins and the nature of the damaging substances. Clinics in Gastroenterology. 1974;3(1):199-211. Not sensitivity or specificity of an identified test. [pmid: 4209120].
Evans Mark J, Harris Heather A, Miller Chris P, et al. Estrogen receptors alpha and beta have similar activities in multiple endothelial cell pathways. Endocrinology. 2002;143(10):3785-3795. Not sensitivity or specificity of an identified test. [pmid: 12239089].
Evans P C, Smith S, Hirschfield G, et al. Recipient HLA-DR3, tumour necrosis factor-alpha promoter allele-2 (tumour necrosis factor-2) and cytomegalovirus infection are interrelated risk factors for chronic rejection of liver grafts. J Hepatol. 2001;34(5):711-715. Not sensitivity or specificity of an identified test. [pmid: 11434617].
Fabbi M, Marimpietri D, Martini S, et al. Tissue transglutaminase is a caspase substrate during apoptosis. Cleavage causes loss of transamidating function and is a biochemical marker of caspase 3 activation. Cell Death and Differentiation. 1999;6(10):992-1001. Not sensitivity or specificity of an identified test. [pmid: 10556977].
Fabiani E, Catassi C. The serum IgA class anti-tissue transglutaminase antibodies in the diagnosis and follow up of coeliac disease. Results of an international multi-centre study. International Working Group on Eu-tTG. European Journal of Gastroenterology & Hepatology. 2001;13(6):659-665. Improper control group. [pmid: 11434591].
Fabiani E, Catassi C, De Rosa S, et al. The serum IgA class anti-tissue transglutaminase antibodies in the diagnosis and follow up of coeliac disease. Results of an international multi-centre study. Pediatrika. 2001;21(10):13-21. Improper control group.
Fabiani E, Catassi C, Villari A et al. Dietary compliance in screening-detected coeliac disease adolescents. Acta Paediatrica (Oslo, Norway - 1992).Supplement 1996;41265–67. Not sensitivity or specificity of an identified test
Fabiani E, Taccari L M, Ratsch I M, et al. Compliance with gluten-free diet in adolescents with screening-detected celiac disease: a 5-year follow-up study. Journal of Pediatrics. 2000;136(6):841-843. Not sensitivity or specificity of an identified test. [pmid: 10839888].
Fabris L, Strazzabosco M, Crosby H A, et al. Characterization and isolation of ductular cells coexpressing neural cell adhesion molecule and Bcl-2 from primary cholangiopathies and ductal plate malformations. American Journal of Pathology. 2000;156(5):1599-1612. Not sensitivity or specificity of an identified test. [pmid: 10793072]. [pmcid: 1876925].
Failla P, Ruberto C, Pagano M C, et al. Celiac disease in Down Syndrome with HLA serological and molecular studies. Journal of Pediatric Gastroenterology and Nutrition. 1996;23(3):303-306. Improper control group. [pmid: 8890082].
Fairman M J, Scott B B, Toothill C, et al. Jejunal mucosal gamma glutamyl transferase activity in coeliac disease. Gut. 1977;18(6):484-487. Not sensitivity or specificity of an identified test. [pmid: 17564]. [pmcid: 1411501].
Fais S, Maiuri L, Pallone F, et al. Gliadin induced changes in the expression of MHC-class II antigens by human small intestinal epithelium. Organ culture studies with coeliac disease mucosa. Gut. 1992;33(4):472-475. Not sensitivity or specificity of an identified test. [pmid: 1582589]. [pmcid: 1374061].
Falchuk K R, Falchuk Z M. Selective immunoglobulin a deficiency, ulcerative colitis, and gluten-sensitive enteropathy--a unique association. Gastroenterology. 1975;69(2):503-506. Not sensitivity or specificity of an identified test. [pmid: 1175883].
Falchuk Z M. Update on gluten-sensitive enteropathy. American Journal of Medicine. 1979;67(6):1085-1096. Not sensitivity or specificity of an identified test. [pmid: 391038].
Falchuk Z M. Gluten-sensitive enteropathy. Clin Gastroenterol. 1983;12(2):475-494. Not sensitivity or specificity of an identified test. [pmid: 6347467].
Falchuk Z M, Strober W. Gluten-sensitive enteropathy: synthesis of antigliadin antibody in vitro. Gut. 1974;15(12):947-952. Not sensitivity or specificity of an identified test. [pmid: 4448409]. [pmcid: 1413076].
Falchuk Z M, Gebhard R L, Sessoms C, et al. An in vitro model of gluten-sensitive enteropathy. Effect of gliadin on intestinal epithelial cells of patients with gluten-sensitive enteropathy in organ culture. Journal of Clinical Investigation. 1974;53(2):487-500. Not sensitivity or specificity of an identified test. [pmid: 11344562]. [pmcid: 301491].
Falchuk Z M, Katz A J, Shwachman H, et al. Gluten-sensitive enteropathy: genetic analysis and organ culture study in 35 families. Scandinavian Journal of Gastroenterology. 1978;13(7):839-843. Not sensitivity or specificity of an identified test. [pmid: 82994].
Falchuk Z M, Nelson D L, Katz A J, et al. Gluten-sensitive enteropathy. Influence of histocompatibility type on gluten sensitivity in vitro. Journal of Clinical Investigation. 1980;66(2):227-233. Not sensitivity or specificity of an identified test. [pmid: 7400313]. [pmcid: 371702].
Falk M C, NG G, Zhang G Y, et al. Predominance of T cell receptor V delta 3 in small bowel biopsies from coeliac disease patients. Clinical and Experimental Immunology. 1994;98(1):78-82. Not sensitivity or specificity of an identified test. [pmid: 7923889]. [pmcid: 1534169].
Fallstrom S P, Kristiansson B, Ryd W. Histological studies of small-intestinal biopsies from infants with low rate of weight gain. Acta Pathol Microbiol Scand Sect A Pathol. 1981;89(6):431-438. Not sensitivity or specificity of an identified test.
Falorni A, Laureti S. Adrenal autoimmunity and correlation with adrenal dysfunction. Endocrinologist. 2000;10(3):145-154. Not sensitivity or specificity of an identified test.
Falorni A, Kockum I, Sanjeevi C B, et al. Pathogenesis of insulin-dependent diabetes mellitus. Bailliere's Clin Endocrinol Metab. 1995;9(1):25-46. Not sensitivity or specificity of an identified test. [pmid: 7726797].
Falth-Magnusson K, Jansson G, Stenhammar L, et al. Intestinal permeability assessed with different-sized polyethylene glycols in children undergoing small-intestinal biopsy for suspected celiac disease. Scandinavian Journal of Gastroenterology. 1989;24(1):40-46. Not sensitivity or specificity of an identified test. [pmid: 2928722].
Farkas G, Buday L, Csermely P, et al. Lipocortin I is not accessible for protein kinase C bound to the cytoplasmic surface of the plasma membrane in streptolysin-O-permeabilized pig granulocytes. Biochimica Et Biophysica Acta. 1994;1220(3):315-322. Not sensitivity or specificity of an identified test. [pmid: 8305505].
Farre C, Esteve M, Curcoy A, et al. Hypertransaminasemia in pediatric celiac disease patients and its prevalence as a diagnostic clue. American Journal of Gastroenterology. 2002;97(12):3176-3181. Not sensitivity or specificity of an identified test. [pmid: 12492207].
Farre C, Humbert P, Vilar P, et al. Serological markers and HLA-DQ2 haplotype among first-degree relatives of celiac patients. Catalonian Coeliac Disease Study Group. Digestive Diseases and Sciences. 1999;44(11):2344-2349. Improper control group. [pmid: 10573385].
Farrell R J, Kelly C P. Diagnosis of celiac sprue. American Journal of Gastroenterology. 2001;96(12):3237-3246. Review article. [pmid: 11774931].
Farrell Richard J, Kelly Ciaran P. Celiac sprue. New England Journal of Medicine. 2002;346(3):180-188. Not sensitivity or specificity of an identified test. [pmid: 11796853].
Farstad I N, Johansen F-E, Vlatkovic L, et al. Heterogeneity of intraepithelial lymphocytes in refractory sprue: Potential implications of CD30 expression. Gut. 2002;51(3):372-378. Not sensitivity or specificity of an identified test. [pmid: 12171959]. [pmcid: 1773363].
Farthing M J, Rees L H, Dawson A M. Male gonadal function in coeliac disease: III. Pituitary regulation. Clinical Endocrinology. 1983;19(6):661-671. Not sensitivity or specificity of an identified test. [pmid: 6418418].
Fasano A. Tissue transglutaminase: the Holy Grail for the diagnosis of celiac disease, at last?. Journal of Pediatrics. 1999;134(2):134-135. Review article. [pmid: 9931515].
Fasano A. Where have all the American celiacs gone?. Acta paediatrica (Oslo, Norway : 1992).Supplement. 1996;41220–24. Not sensitivity or specificity of an identified test
Fasano A, Catassi C. Current approaches to diagnosis and treatment of celiac disease: an evolving spectrum. Gastroenterology. 2001;120(3):636-651. Not sensitivity or specificity of an identified test. [pmid: 11179241].
Fasano Alessio. Celiac disease--how to handle a clinical chameleon. New England Journal of Medicine. 2003;348(25):2568-2570. Not sensitivity or specificity of an identified test. [pmid: 12815143].
Fasano Alessio, Berti Irene, Gerarduzzi Tania, et al. Prevalence of celiac disease in at-risk and not-at-risk groups in the United States: a large multicenter study. Archives of Internal Medicine. 2003;163(3):286-292. Not sensitivity or specificity of an identified test. [pmid: 12578508].
Faulkner-Hogg K B, Selby W S, Loblay R H. Dietary analysis in symptomatic patients with coeliac disease on a gluten-free diet: the role of trace amounts of gluten and non-gluten food intolerances. Scandinavian Journal of Gastroenterology. 1999;34(8):784-789. Not sensitivity or specificity of an identified test. [pmid: 10522611].
Fausa D, Thune P. Gastrointestinal dysfunction in dermatitis herpetiformis. Scandinavian Journal of Gastroenterology. 1974;9(27 sup.):No 27Not sensitivity or specificity of an identified test.
Fausa O, Eeg Larsen T, Husby G, et al. Gastrointestinal investigations in dermatitis herpetiformis. Acta Derm-Venereol. 1975;55(3):203-206. Not sensitivity or specificity of an identified test. [pmid: 50693].
Favatier F, Bornman L, Hightower L E, et al. Variation in hsp gene expression and Hsp polymorphism: Do they contribute to differential disease susceptibility and stress tolerance?. Cell Stress Chaperones. 1997;2(3):141-155. Not sensitivity or specificity of an identified test. [pmid: 9314601]. [pmcid: 312991].
Fedrick J A, Pandey J P, Verkasalo M, et al. Immunoglobulin allotypes and the immune response to wheat gliadin in a Finnish population with celiac disease. Experimental and Clinical Immunogenetics. 1985;2(4):185-190. Not sensitivity or specificity of an identified test. [pmid: 3917148].
Feeley K M, Heneghan M A, Stevens F M, et al. Lymphocytic gastritis and coeliac disease: evidence of a positive association. Journal of Clinical Pathology. 1998;51(3):207-210. Not sensitivity or specificity of an identified test. [pmid: 9659261]. [pmcid: 500640].
Feighery C. Coeliac disease. Br Med J. 1999;319(7204):236-239. Not sensitivity or specificity of an identified test. [pmid: 10417090]. [pmcid: 1116331].
Feighery C. Coeliac disease, auto-immunity and thyroid disease. Ital J Gastroenterol Hepatol. 1999;31(4):288-289. Not sensitivity or specificity of an identified test. [pmid: 10425572].
Feighery, C F. Coeliac disease: How much of what is toxic to whom?. Gut. 1998;43(2):164-165. Not sensitivity or specificity of an identified test. [pmid: 10189837]. [pmcid: 1727227].
Feighery C, Abuzakouk M, Liddy C, et al. Endomysial antibody detection using human umbilical cord tissue as substrate: reactivity of cells in Wharton's jelly. British Journal of Biomedical Science. 1998;55(2):107-110. Improper control group. [pmid: 10198467].
Feighery C, Weir D G, Whelan A, et al. Diagnosis of gluten-sensitive enteropathy: is exclusive reliance on histology appropriate?. Eur J Gastroenterol Hepatol. 1998;10(11):919-925. Unable to obtain full article. [pmid: 9872613].
Feighery C, Whelan A, Weir D G. Endomysium: Autoantigen in coeliac disease. European Journal of Gastroenterology & Hepatology. 1997;9(7):655-656. Not sensitivity or specificity of an identified test. [pmid: 9262971].
Feighery L, Collins C, Feighery C, et al. Anti-transglutaminase antibodies and the serological diagnosis of coeliac disease. British Journal of Biomedical Science. 2003;60(1):14-18. Not sensitivity or specificity of an identified test. [pmid: 12680625].
Feighery L, Lynch S, Kilmartin C, et al. Flow-cytometric detection of lactase expression in normal and coeliac intestinal epithelium. European Journal of Gastroenterology & Hepatology. 2001;13(8):897-902. Not sensitivity or specificity of an identified test. [pmid: 11507352].
Feng J F, Rhee S G, Im M J. Evidence that phospholipase delta1 is the effector in the Gh (transglutaminase II)-mediated signaling. Journal of Biological Chemistry. 1996;271(28):16451-16454. Not sensitivity or specificity of an identified test. [pmid: 8663582].
Fennessy M, Metcalfe K, Hitman G A, et al. A gene in the HLA class I region contributes to susceptibility to IDDM in the Finnish population. Childhood Diabetes in Finland (DiMe) Study Group. Diabetologia. 1994;37(9):937-944. Not sensitivity or specificity of an identified test. [pmid: 7806025].
Ferfoglia G, Pulitano R, Sategna-Guidetti C. Do dietary antibodies still play a role in the diagnosis and follow-up of coeliac disease? A comparison among different serological tests. Panminerva Medica. 1995;37(2):55-59. Improper control group. [pmid: 8637769].
Ferguson A. Celiac disease, an eminently treatable condition, may be underdiagnosed in the United States. American Journal of Gastroenterology. 1997;92(8):1252-1254. Not sensitivity or specificity of an identified test. [pmid: 9260784].
Ferguson A. Coeliac disease. Prescr J. 1997;37(4):206-212. Not sensitivity or specificity of an identified test.
Ferguson A. Coeliac disease research and clinical practice: Maintaining momentum into the twenty-first century. Bailliere's Clin Gastroenterol. 1995;9(2):395-412. Not sensitivity or specificity of an identified test. [pmid: 7549033].
Ferguson A. The immune system and mucosal transformation - Historical perspective. Digestion. 1990;46(Suppl 2):255-261. Not sensitivity or specificity of an identified test. [pmid: 2262058].
Ferguson A. Intraepithelial lymphocytes of the small intestine. Part I: Morphology and experimental immunology of intraepithelial lymphocytes. Gut. 1977;18(11):921-937. Not sensitivity or specificity of an identified test. [pmid: 338444]. [pmcid: 1411743].
Ferguson A, Kingstone K. Coeliac disease and malignancies. Acta Paediatrica (Oslo, Norway - 1992).Supplement 1996;41278–81. Not sensitivity or specificity of an identified test
Ferguson A, Murray D. Quantitation of intraepithelial lymphocytes in human jejunum. Gut. 1971;12(12):988-994. Not sensitivity or specificity of an identified test. [pmid: 5157137]. [pmcid: 1411995].
Ferguson A, Ziegler K. Intraepithelial lymphocyte mitosis in a jejunal biopsy correlates with intraepithelial lymphocyte count, irrespective of diagnosis. Gut. 1986;27(6):675-679. Not sensitivity or specificity of an identified test. [pmid: 3721290]. [pmcid: 1433342].
Ferguson A, Arranz E, O'Mahony S. Spectrum of expression of intestinal cellular immunity: proposal for a change in diagnostic criteria of celiac disease. Annals of Allergy. 1993;71(1):29-32. Not sensitivity or specificity of an identified test. [pmid: 8328709].
Ferguson A, Arranz E, O'Mahony S. Clinical and pathological spectrum of coeliac disease - active, silent, latent, potential. Gut. 1993;34(2):150-151. Not sensitivity or specificity of an identified test. [pmid: 8432463]. [pmcid: 1373959].
Ferguson A, Blackwell J N, Barnetson R S. Effects of additional dietary gluten on the small-intestinal mucosa of volunteers and of patients with dermatitis herpetiformis. Scandinavian Journal of Gastroenterology. 1987;22(5):543-549. Not sensitivity or specificity of an identified test. [pmid: 3629179].
Ferguson A, Gillett H, Humphreys K et al. Heterogeneity of celiac disease: clinical, pathological, immunological, and genetic. Annals of the New York Academy of Sciences 1998;859112–120. Not sensitivity or specificity of an identified test
Ferguson A, MacDonald T T, McClure J P, et al. Cell-mediated immunity to gliadin within the small-intestinal mucosa in coeliac disease. Lancet. 1975;1(7912):895-897. Not sensitivity or specificity of an identified test. [pmid: 47539].
Ferguson A, McClure J P, Townley R R. Intraepithelial lymphocyte counts in small intestinal biopsies from children with diarrhoea. Acta Paediatrica Scandinavica. 1976;65(5):541-546. Unable to extract data. [pmid: 961407].
Ferguson A, Mowat A M, Strobel S, et al. T-cell mediated immunity in food allergy. Annals of Allergy. 1983;51(2 Pt 2):246-248. Not sensitivity or specificity of an identified test. [pmid: 6603801].
Ferguson A, Ziegler K, Strobel S. Gluten intolerance (coeliac disease). Annals of Allergy. 1984;53(6 Pt 2):637-642. Not sensitivity or specificity of an identified test. [pmid: 6391293].
Ferguson M M, Wray D, Carmichael H A. Coeliac disease associated with recurrent aphthae. Gut. 1980;21(3):223-226. Not sensitivity or specificity of an identified test. [pmid: 7399324]. [pmcid: 1420353].
Ferguson R, Asquith P, Cooke W T. The cellular infiltrate of the jejunum in coeliac patients with complicating lymphoma. Gut. 1974;15(4):338-339. Not sensitivity or specificity of an identified test. [pmid: 4434954].
Ferguson R, Asquith P, Cooke W T. The jejunal cellular infiltrate in coeliac disease complicated by lymphoma. Gut. 1974;15(6):458-461. Not sensitivity or specificity of an identified test. [pmid: 4434954]. [pmcid: 1412999].
Ferguson R, Basu M K, Asquith P, et al. Jejunal mucosal abnormalities in patients with recurrent aphthous ulceration. British Medical Journal. 1976;1(6000):11-13. Not sensitivity or specificity of an identified test. [pmid: 1247715]. [pmcid: 1638254].
Fernandez L, Fernandez-Arquero M, Gual L, et al. Triplet repeat polymorphism in the transmembrane region of the MICA gene in celiac disease. Tissue Antigens. 2002;59(3):219-222. Not sensitivity or specificity of an identified test. [pmid: 12074713].
Fernandez N, Hitman G A, Festenstein H, et al. Novel HLA class II-associated structural patterns in coeliac disease and type I diabetes. Clinical and Experimental Immunology. 1988;72(3):362-366. Not sensitivity or specificity of an identified test. [pmid: 2901925]. [pmcid: 1541555].
Fernandez-Arquero M, Caldes T, Casado E, et al. Polymorphism within the HLA-DQB1*02 promoter associated with susceptibility to coeliac disease. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1998;25(1):1-3. Not sensitivity or specificity of an identified test. [pmid: 9587738].
Fernandez-Arquero M, Figueredo M A, Maluenda C, et al. HLA-linked genes acting as additive susceptibility factors in celiac disease. Human Immunology. 1995;42(4):295-300. Improper control group. [pmid: 7558913].
Fernandez-Arquero M, Polanco I, Escobar H, et al. HLA-DQ alleles and susceptibility to celiac disease in Spanish children. Tissue Antigens. 1995;45(2):145-147. Improper control group. [pmid: 7792763].
Fernandez-Calle P, Codoceo R, Polanco I, et al. Is an intestinal permeability test a valid marker for slight dietary transgressions in adolescents with coeliac disease?. Gut. 1993;34(6):774-777. Not sensitivity or specificity of an identified test. [pmid: 8314509]. [pmcid: 1374260].
Ferrante P, Petronzelli F, Mariani P, et al. Oligotyping of Italian celiac patients with the 11th International Histocompatibility Workshop reagents. Tissue Antigens. 1992;39(1):38-39. Improper control group. [pmid: 1542877].
Ferreira M, Davies S L, Butler M, et al. Endomysial antibody: is it the best screening test for coeliac disease?. Gut. 1992;33(12):1633-1637. Improper control group. [pmid: 1487164]. [pmcid: 1379574].
Festenstein H, Nyulassy S. Workshop on HLA and disease. Transplantation Proceedings. 1979;11(1):1183-1185. Not sensitivity or specificity of an identified test. [pmid: 313097].
Festoff B W, Suo Z, Citron B A. Plasticity and stabilization of neuromuscular and CNS synapses: interactions between thrombin protease signaling pathways and tissue transglutaminase. International Review of Cytology 2001;211153–177. Not sensitivity or specificity of an identified test
Festoff B W, Suo Z, Citron B A. Prospects for the pharmacotherapy of amyotrophic lateral sclerosis: Old strategies and new paradigms for the third millennium. Cns Drugs. 2003;17(10):699-717. Not sensitivity or specificity of an identified test. [pmid: 12873154].
Fesus L. Transglutaminase-catalyzed protein cross-linking in the molecular program of apoptosis and its relationship to neuronal processes. Cellular and Molecular Neurobiology. 1998;18(6):683-694. Not sensitivity or specificity of an identified test. [pmid: 9876874].
Fesus L, Arato G. Quantitation of tissue transglutaminase by a sandwich ELISA system. Journal of Immunological Methods. 1986;94(12):131-136. Not sensitivity or specificity of an identified test. [pmid: 2878048].
Fesus L, Thomazy V. Searching for the function of tissue transglutaminase: its possible involvement in the biochemical pathway of programmed cell death. Advances in Experimental Medicine and Biology 1988;231119–134. Not sensitivity or specificity of an identified test
Fesus L, Erdei A, Sandor M, et al. The influence of tissue transglutaminase on the function of Fc receptors. Molecular Immunology. 1982;19(1):39-43. Not sensitivity or specificity of an identified test. [pmid: 6123075].
Fesus L, Falus A, Erdei A, et al. Human beta 2-microglobulin is a substrate of tissue transglutaminase: polymerization in solution and on the cell surface. Journal of Cell Biology. 1981;89(3):706-710. Not sensitivity or specificity of an identified test. [pmid: 6166622].
Fesus L, Metsis M L, Muszbek L, et al. Transglutaminase-sensitive glutamine residues of human plasma fibronectin revealed by studying its proteolytic fragments. European Journal of Biochemistry / Febs. 1986;154(2):371-374. Not sensitivity or specificity of an identified test. [pmid: 2867902].
Fesus L, Nagy L, Basilion J P, et al. Retinoic acid receptor transcripts in human umbilical vein endothelial cells. Biochemical and Biophysical Research Communications. 1991;179(1):32-38. Not sensitivity or specificity of an identified test. [pmid: 1715692].
Fesus L, Tarcsa E, Kedei N, et al. Degradation of cells dying by apoptosis leads to accumulation of epsilon(gamma-glutamyl)lysine isodipeptide in culture fluid and blood. Febs Lett. 1991;284(1):109-112. Not sensitivity or specificity of an identified test. [pmid: 1676376].
Fesus Laszlo, Piacentini Mauro. Transglutaminase 2: an enigmatic enzyme with diverse functions. Trends in Biochemical Sciences. 2002;27(10):534-539. Not sensitivity or specificity of an identified test. [pmid: 12368090].
Feurle G E. Pathophysiology of diarrhea in patients with familial amyloid neuropathy. Digestion. 1987;36(1):13-17. Not sensitivity or specificity of an identified test. [pmid: 3493933].
Fielding J F, Doyle G D. Coeliac disease amongst adolescents previously labelled as coeliacs on clinical grounds. J Ir Coll Phys Surg. 1978;7(3):89-91. Not sensitivity or specificity of an identified test.
Fine K D. The prevalence of occult gastrointestinal bleeding in celiac sprue. New England Journal of Medicine. 1996;334(18):1163-1167. Not sensitivity or specificity of an identified test. [pmid: 8602182].
Fine K D, Do K, Schulte K, et al. High prevalence of celiac sprue-like HLA-DQ genes and enteropathy in patients with the microscopic colitis syndrome. American Journal of Gastroenterology. 2000;95(8):1974-1982. Improper control group. [pmid: 10950045].
Fine K D, Lee E L, Meyer R L. Colonic histopathology in untreated celiac sprue or refractory sprue: is it lymphocytic colitis or colonic lymphocytosis?. Human Pathology. 1998;29(12):1433-1440. Not sensitivity or specificity of an identified test. [pmid: 9865829].
Fine K D, Meyer R L, Lee E L. The prevalence and causes of chronic diarrhea in patients with celiac sprue treated with a gluten-free diet. Gastroenterology. 1997;112(6):1830-1838. Not sensitivity or specificity of an identified test. [pmid: 9178673].
Fine K D, Ogunji F, Saloum Y, et al. Celiac sprue: another autoimmune syndrome associated with hepatitis C. American Journal of Gastroenterology. 2001;96(1):138-145. Not sensitivity or specificity of an identified test. [pmid: 11197243].
Finney S, Seale L, Sawyer R T, et al. Tridegin, a new peptidic inhibitor of factor XIIIa, from the blood-sucking leech Haementeria ghilianii. Biochemical Journal. 1997;324(Pt 3):797-805. Not sensitivity or specificity of an identified test. [pmid: 9210403]. [pmcid: 1218495].
Fischer G F, Mayr W R. Molecular genetics of the HLA complex. Wiener Klinische Wochenschrift. 2001;113(2021):814-824. Not sensitivity or specificity of an identified test. [pmid: 11732117].
Fitzpatrick K P, Sherman P M, Ipp M, et al. Screening for celiac disease in children with recurrent abdominal pain. Journal of Pediatric Gastroenterology and Nutrition. 2001;33(3):250-252. Not sensitivity or specificity of an identified test. [pmid: 11593117].
Fivenson D P, Douglass M C, Nickoloff B J. Cutaneous expression of Thy-1 in mycosis fungoides. American Journal of Pathology. 1992;141(6):1373-1380. Not sensitivity or specificity of an identified test. [pmid: 1281618]. [pmcid: 1886763].
Fladby T, Kampman M T, Loseth S, et al. Human leukocyte antigen class I in polymyositis: Leukocyte infiltrates, regeneration, and impulse block. Muscle Nerve. 1997;20(12):1534-1540. Not sensitivity or specificity of an identified test. [pmid: 9390666].
Fleckenstein Burkhard, Molberg Oyvind, Qiao Shuo, et al. Gliadin T cell epitope selection by tissue transglutaminase in celiac disease. Role of enzyme specificity and pH influence on the transamidation versus deamidation process. Journal of Biological Chemistry. 2002;277(37):34109-34116. Not sensitivity or specificity of an identified test. [pmid: 12093810].
Fleming S C, Duncan A, Russell R I, et al. Measurement of sugar probes in serum: an alternative to urine measurement in intestinal permeability testing. Clinical Chemistry. 1996;42(3):445-448. Not sensitivity or specificity of an identified test. [pmid: 8598111].
Flint A, McCoy J P, Schade W J, et al. Cervical carcinoma antigen: distribution in neoplastic lesions of the uterine cervix and comparison to other tumor markers. Gynecologic Oncology. 1988;30(1):63-70. Not sensitivity or specificity of an identified test. [pmid: 2452772].
Floreani A, Betterle C, Baragiotta A, et al. Prevalence of coeliac disease in primary biliary cirrhosis and of antimitochondrial antibodies in adult coeliac disease patients in Italy. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(4):258-261. Not sensitivity or specificity of an identified test. [pmid: 12038809].
Floreani A, Chiaramonte M, Venturini R, et al. Antigliadin antibody classes in chronic liver disease. Italian Journal of Gastroenterology. 1992;24(8):457-460. Not sensitivity or specificity of an identified test. [pmid: 1421449].
Floren C H, Alm P. Defective synthesis of apolipoprotein A-I in jejunal mucosa in coeliac disease. Scandinavian Journal of Gastroenterology. 1988;23(7):856-860. Not sensitivity or specificity of an identified test. [pmid: 3067329].
Fluge G, Aksnes L. Autoradiographic localization of a gluten peptide during organ culture of human duodenal mucosa. Journal of Pediatric Gastroenterology and Nutrition. 1983;2(3):452-458. Not sensitivity or specificity of an identified test. [pmid: 6886950].
Fluge G, Aksnes L. Influence of cow's milk proteins and gluten on human duodenal mucosa in organ culture. Journal of Pediatric Gastroenterology and Nutrition. 1990;11(4):481-488. Not sensitivity or specificity of an identified test. [pmid: 2262836].
Fluge G, Aksnes L. Labelling indices after 3H-thymidine incorporation during organ culture of duodenal mucosa in coeliac disease. Scandinavian Journal of Gastroenterology. 1981;16(7):921-928. Not sensitivity or specificity of an identified test. [pmid: 7323718].
Fluge G, Aksnes L. Mitotic rate and mitotic time in coeliac and non-coeliac duodenal biopsies maintained in organ culture. Virchows Archiv. B, Cell Pathology Including Molecular Pathology. 1981;38(2):159-167. Not sensitivity or specificity of an identified test.
Fluge G, Aksnes L. Morphological and morphometric assessment of human duodenal biopsies maintained in organ culture. In vitro influences of gluten in coeliac disease. Scandinavian Journal of Gastroenterology. 1981;16(4):555-567. Not sensitivity or specificity of an identified test. [pmid: 7323718].
Fluge G, Aksnes L. Quantification of immunoglobulins after organ culture of human duodenal mucosa. Journal of Pediatric Gastroenterology and Nutrition. 1983;2(1):62-70. Not sensitivity or specificity of an identified test. [pmid: 6886950].
Fluge G, Andersen K J, Aksnes L, et al. Brush border and lysosomal marker enzyme profiles in duodenal mucosa from coeliac patients before and after organ culture. Scandinavian Journal of Gastroenterology. 1982;17(4):465-472. Not sensitivity or specificity of an identified test. [pmid: 6813957].
Fluge O, Sletten K, Fluge G, et al. In vitro toxicity of purified gluten peptides tested by organ culture. Journal of Pediatric Gastroenterology and Nutrition. 1994;18(2):186-192. Not sensitivity or specificity of an identified test. [pmid: 8014766].
Flynn J C, Wan Q, Panos J C, et al. Coexpression of susceptible and resistant HLA class II transgenes in murine experimental autoimmune thyroiditis: DQ8 molecules downregulate DR3-mediated thyroiditis. J Autoimmun. 2002;18(3):213-220. Not sensitivity or specificity of an identified test. [pmid: 12126634].
Fois A, Vascotto M, Di Bartolo R M, et al. Celiac disease and epilepsy in pediatric patients. Child's Nervous System - Chns - Official Journal of the International Society for Pediatric Neurosurgery. 1994;10(7):450-454. Not sensitivity or specificity of an identified test. [pmid: 7842435].
Foldes-Papp Zeno, Demel Ulrike, Berry Desiree, et al. Tissue transglutaminase antibody determination in celiac disease. Analysis of diagnostic specificity of anti-human IgA-type assays. Journal of Immunoassay & Immunochemistry. 2002;23(2):211-227. Improper control group. [pmid: 12033644].
Fontana M, Boldorini R, Zuin G, et al. Ultrastructural changes in the duodenal mucosa of HIV-infected children. Journal of Pediatric Gastroenterology and Nutrition. 1993;17(3):255-259. Not sensitivity or specificity of an identified test. [pmid: 8271123].
Fonti R, Limite G, Sodano A, et al. Sentinel lymph node identification in breast cancer patients. La Radiologia Medica. 2002;103(4):370-377. Not sensitivity or specificity of an identified test. [pmid: 12107387].
Fordtran J S, Rector F C, Locklear T W, et al. Water and solute movement in the small intestine of patients with sprue. Journal of Clinical Investigation. 1967;46(3):287-298. Not sensitivity or specificity of an identified test. [pmid: 6023768]. [pmcid: 297050].
Foreman K E, Bacon P E, Hsi E D, et al. In situ polymerase chain reaction-based localization studies support role of human herpesvirus-8 as the cause of two AIDS-related neoplasms: Kaposi's sarcoma and body cavity lymphoma. Journal of Clinical Investigation. 1997;99(12):2971-2978. Not sensitivity or specificity of an identified test. [pmid: 9185521]. [pmcid: 508149].
Forget P, Grandfils C, Van Cutsem J L, et al. Diamine oxidase in serum and small intestinal biopsy tissue in childhood celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1986;5(3):379-383. Not sensitivity or specificity of an identified test. [pmid: 3088248].
Forgeur A, Willems F, Winand J, et al. Natriuretic peptide receptors of type A in human neuroblastomas. Neuroendocrinology. 1999;70(4):288-294. Not sensitivity or specificity of an identified test. [pmid: 10529624].
Fornasieri A, Sinico R A, Maldifassi P, et al. IgA-antigliadin antibodies in IgA mesangial nephropathy (Berger's disease). British Medical Journal (Clinical Research Ed.). 1987;295(6590):78-80. Not sensitivity or specificity of an identified test. [pmid: 3113643]. [pmcid: 1246960].
Forsberg Gote, Hernell Olle, Melgar Silvia, et al. Paradoxical coexpression of proinflammatory and down-regulatory cytokines in intestinal T cells in childhood celiac disease. Gastroenterology. 2002;123(3):667-678. Not sensitivity or specificity of an identified test. [pmid: 12198691].
Fotherby K J, Wraight E P, Neale G. 51Cr-EDTA/14C-mannitol intestinal permeability test. Clinical use in screening for coeliac disease. Scandinavian Journal of Gastroenterology. 1988;23(2):171-177. Not sensitivity or specificity of an identified test. [pmid: 3129775].
Fotoulaki M, Nousia-Arvanitakis S, Augoustidou-Savvopoulou P, et al. Clinical application of immunological markers as monitoring tests in celiac disease. Digestive Diseases and Sciences. 1999;44(10):2133-2138. Not sensitivity or specificity of an identified test. [pmid: 10548368].
Fottrell P F. Intestinal peptide transport and hydrolysis in health and disease. Ir J Med Sci. 1979;148(4):123-134. Not sensitivity or specificity of an identified test. [pmid: 393650].
Fraga M, Brousset P, Schlaifer D, et al. Bone marrow involvement in anaplastic large cell lymphoma. Immunohistochemical detection of minimal disease and its prognostic significance. American Journal of Clinical Pathology. 1995;103(1):82-89. Not sensitivity or specificity of an identified test. [pmid: 7817951].
Fraij B M. GTP hydrolysis by human tissue transglutaminase homologue. Biochemical and Biophysical Research Communications. 1996;218(1):45-49. Not sensitivity or specificity of an identified test. [pmid: 8573173].
Fraij B M, Gonzales R A. Organization and structure of the human tissue transglutaminase gene. Biochimica Et Biophysica Acta. 1997;1354(1):65-71. Not sensitivity or specificity of an identified test. [pmid: 9375794].
Fraij B M, Gonzales R A. A third human tissue transglutaminase homologue as a result of alternative gene transcripts. Biochimica Et Biophysica Acta. 1996;1306(1):63-74. Not sensitivity or specificity of an identified test. [pmid: 8611626].
Fraij B M, Birckbichler P J, Patterson M K, et al. A retinoic acid-inducible mRNA from human erythroleukemia cells encodes a novel tissue transglutaminase homologue. Journal of Biological Chemistry. 1992;267(31):22616-22623. Not sensitivity or specificity of an identified test. [pmid: 1358880].
Francis James, Carty John E, Scott Brian B. The prevalence of coeliac disease in rheumatoid arthritis. European Journal of Gastroenterology & Hepatology. 2002;14(12):1355-1356. Not sensitivity or specificity of an identified test. [pmid: 12468957].
Franklin J L, Asquith P, Rosenberg I H. The occurrence of cystic fibrosis and celiac sprue within a single sibship. American Journal of Digestive Diseases. 1974;19(2):149-155. Not sensitivity or specificity of an identified test. [pmid: 4811169].
Fraser J S, Ciclitira P J. Pathogenesis of coeliac disease: implications for treatment. World Journal of Gastroenterology - Wjg. 2001;7(6):772-776. Not sensitivity or specificity of an identified test. [pmid: 11854898].
Fraser-Reynolds K A, Butzner J D, Stephure D K, et al. Use of immunoglobulin A-antiendomysial antibody to screen for celiac disease in North American children with type 1 diabetes. Diabetes Care. 1998;21(11):1985-1989. Improper control group. [pmid: 9802755].
Frazzoni M, Lonardo A, Grisendi A, et al. Are routine duodenal and antral biopsies useful in the management of “functional” dyspepsia? A diagnostic and therapeutic study. Journal of Clinical Gastroenterology. 1993;17(2):101-108. Not sensitivity or specificity of an identified test. [pmid: 8409311].
Freedman A R, Macartney J C, Nelufer J M, et al. Timing of infiltration of T lymphocytes induced by gluten into the small intestine in coeliac disease. Journal of Clinical Pathology. 1987;40(7):741-745. Not sensitivity or specificity of an identified test. [pmid: 2957394]. [pmcid: 1141090].
Freeman H J. Failure of added dietary gluten to induce small intestinal histopathological changes in patients with watery diarrhea and lymphocytic colitis. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 1996;10(7):436-439. Not sensitivity or specificity of an identified test. [pmid: 9113884].
Freeman H J. Small intestinal mucosal biopsy for investigation of diarrhea and malabsorption in adults. Gastrointestinal Endoscopy Clinics of North America. 2000;10(4):739-53, Vii. Not sensitivity or specificity of an identified test. [pmid: 11036541].
Freeman H J. Solid-phase ELISA for tissue transglutaminase, an endomysial target for possible serological diagnosis of celiac disease. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 1998;12(5):323-324. Not sensitivity or specificity of an identified test. [pmid: 9773210].
Freeman H J. Biopsy-defined adult celiac disease in Asian-Canadians. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 2003;17(7):433-436. Not sensitivity or specificity of an identified test. [pmid: 12915916].
Freeman H J. Celiac-associated autoimmune thyroid disease: A study of 16 patients with overt hypothyroidism: MALADIE THYROIDIENNE AUTO-IMMUNE DE NATURE COELIAQUE: ETUDE PORTANT SUR 16 PATIENTS ATTEINTS D'HYPOTHYROIDIE AVEREE. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 1995;9(5):242-246. Not sensitivity or specificity of an identified test.
Freeman H J. Clinical spectrum of biopsy defined celiac disease in the elderly. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 1995;9(1):42-46. Not sensitivity or specificity of an identified test.
Freeman H J. Free perforation due to intestinal lymphoma in biopsy-defined or suspected celiac disease. Journal of Clinical Gastroenterology. 2003;37(4):299-302. Not sensitivity or specificity of an identified test. [pmid: 14506386].
Freeman H J. Survey of gastroenterologists on the diagnosis and treatment of adult patients with celiac disease in British Columbia. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 1998;12(2):149-152. Not sensitivity or specificity of an identified test. [pmid: 9559209].
Freeman H J. Topography of lectin binding sites in celiac sprue. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 1992;6(5):271-276. Not sensitivity or specificity of an identified test.
Freemark M, Levitsky L L. Screening for celiac disease in children with type 1 diabetes: Two views of the controversy. Diabetes Care. 2003;26(6):1932-1939. Not sensitivity or specificity of an identified test. [pmid: 12766138].
Freier S. Paediatric gastrointestinal allergy. Clin Allergy. 1973;3(Suppl):597-618. Not sensitivity or specificity of an identified test. [pmid: 4620910].
Frew A J, Bright S, Shewry P R, et al. Proliferative response of lymphocytes of normal individuals to wheat proteins (Gliadins). Int Arch Allergy Appl Immunol. 1980;62(2):162-167. Not sensitivity or specificity of an identified test. [pmid: 7372365].
Frezal J, Rey J. Genetics of disorders of intestinal digestion and absorption. Advances in Human Genetics 1970;1275–336. Not sensitivity or specificity of an identified test
Fric P, Lojda Z, Jodl J. Heterogeneity of enzymes of small-intestinal mucosa in malabsorption syndrome. Ceskoslovenska Gastroenterologie a Vyziva. 1968;22(4):235-249. Not sensitivity or specificity of an identified test. [pmid: 5666309].
Fric P, Lojda Z, Jodl J, et al. Analysis of peroral jejunal biopsies in clinically asymptomatic parents of children with celiac sprue. Digestion. 1969;2(1):35-42. Not sensitivity or specificity of an identified test. [pmid: 5776465].
Friedrich M, Villena-Heinsen C, He J, et al. Correlation between immunoreactivity for transglutaminase K and for markers of proliferation and differentiation in normal breast tissue and breast carcinomas. European Journal of Gynaecological Oncology. 1998;19(5):444-448. Not sensitivity or specificity of an identified test. [pmid: 9863908].
Friedrich M, Villena-Heinsen C, He J, et al. Expression of transglutaminase K in normal cervix tissue and cervix carcinomas. Histochem J. 1999;31(1):13-18. Not sensitivity or specificity of an identified test. [pmid: 10405818].
Friedrichs B, Riedmiller H, Goebel H W, et al. Immunological characterization and activity of transglutaminases in human normal and malignant prostate and in prostate cancer cell lines. Urological Research. 1995;23(5):301-310. Not sensitivity or specificity of an identified test. [pmid: 8839386].
Friis B, Karup Pedersen F, Schiodt M. Immunological studies in two children with recurrent parotitis. Acta Paediatr Scand. 1983;72(2):265-268. Not sensitivity or specificity of an identified test. [pmid: 6340414].
Friis S U, Gudmand-Hoyer E. Screening for coeliac disease in adults by simultaneous determination of IgA and IgG gliadin antibodies. Scandinavian Journal of Gastroenterology. 1986;21(9):1058-1062. Improper control group. [pmid: 3810005].
Friis S U, Larsen K, Boserup J, et al. Gliadin antibody titers in coeliac patients during short-term provocations with bread made from wheat flour and enzymatic digested wheat flour. European Journal of Gastroenterology & Hepatology. 1990;2(5):361-365. Not sensitivity or specificity of an identified test.
Friis S U, Noren O, Sjostrom H et al. Patients with coeliac disease have a characteristic gliadin antibody pattern. Clinica Chimica Acta 1986;International Journal of Clinical Chemistry;155(2):133–141. Not sensitivity or specificity of an identified test
Friis S, Dabelsteen E, Sjostrom H, et al. Gliadin uptake in human enterocytes. Differences between coeliac patients in remission and control individuals. Gut. 1992;33(11):1487-1492. Not sensitivity or specificity of an identified test. [pmid: 1452073]. [pmcid: 1379533].
Frisman D M, McCarthy W F, Schleiff P, et al. Immunocytochemistry in the differential diagnosis of effusions: use of logistic regression to select a panel of antibodies to distinguish adenocarcinomas from mesothelial proliferations. Modern Pathology - an Official Journal of the United States and Canadian Academy of Pathology, Inc. 1993;6(2):179-184. Not sensitivity or specificity of an identified test. [pmid: 8483888].
Frisoni G B, Carabellese N, Longhi M, et al. Is celiac disease associated with Alzheimer's disease?. Acta Neurologica Scandinavica. 1997;95(3):147-151. Not sensitivity or specificity of an identified test. [pmid: 9088382].
Frisoni M, Volta U, Valentini R A, et al. Antigliadin antibody levels in symptomless celiac disease. Digestive Diseases and Sciences. 1989;34(10):1639-1640. Review article. [pmid: 2791820].
Fritz P, Mischlinski A, Multhaupt H et al. Application of a new electrophoresis technique (2D cryostat section electrophoresis) to synovial tissue of RA patients and comparison with immunohistochemical staining methods. Acta Histochemica.Supplementband 1990;40121–126. Not sensitivity or specificity of an identified test
Fronek Z, Cheung M M, Hanbury A M, et al. Molecular analysis of HLA DP and DQ genes associated with dermatitis herpetiformis. Journal of Investigative Dermatology. 1991;97(5):799-802. Not sensitivity or specificity of an identified test. [pmid: 1919044].
Frustaci Andrea, Cuoco Lucio, Chimenti Cristina, et al. Celiac disease associated with autoimmune myocarditis. Circulation. 2002;105(22):2611-2618. Not sensitivity or specificity of an identified test. [pmid: 12045166].
Fry L. Dermatitis herpetiformis. Bailliere's Clinical Gastroenterology. 1995;9(2):371-393. Not sensitivity or specificity of an identified test. [pmid: 7549032].
Fry L. Dermatitis herpetiformis Problems, progress and prospects. Eur J Dermatol. 2002;12(6):523-531. Not sensitivity or specificity of an identified test. [pmid: 12459520].
Fry L, McMinn R M. Morphology and functional cytology of the small intestinal mucosa in malabsorptive disorders and other diseases. Journal of Clinical Pathology. 1966;19(3):260-265. Not sensitivity or specificity of an identified test. [pmid: 5937611]. [pmcid: 473250].
Fry L, Seah P P, Hoffbrand A V. Dermatitis herpetiformis. Clin Gastroenterol. 1974;3(1):145-157. Not sensitivity or specificity of an identified test. [pmid: 4599262].
Fry L, Seah P P, McMinn R M, et al. Lymphocytic infiltration of epithelium in diagnosis of gluten-sensitive enteropathy. British Medical Journal. 1972;3(823):371-374. Not sensitivity or specificity of an identified test. [pmid: 5070159]. [pmcid: 1785442].
Frye M, Bargon J, Lembcke B, et al. Differential expression of human alpha- and beta-defensins mRNA in gastrointestinal epithelia. European Journal of Clinical Investigation. 2000;30(8):695-701. Not sensitivity or specificity of an identified test. [pmid: 10964161].
Fugger L, Svejgaard A. The HLA-DQ7 and -DQ8 associations in DR4-positive rheumatoid arthritis patients. Tissue Antigens. 1997;50(5):494-500. Not sensitivity or specificity of an identified test. [pmid: 9389324].
Fujimoto M, Kanzaki H, Nakayama H, et al. Requirement for transglutaminase in progesterone-induced decidualization of human endometrial stromal cells. Endocrinology. 1996;137(3):1096-1101. Not sensitivity or specificity of an identified test. [pmid: 8603579].
Fujimoto N, Tajima S, Ishibashi A. Elastin peptides induce migration and terminal differentiation of cultured keratinocytes via 67 kDa elastin receptor in vitro: 67 kDa elastin receptor is expressed in the keratinocytes eliminating elastic materials in elastosis perforans serpiginosa. Journal of Investigative Dermatology. 2000;115(4):633-639. Not sensitivity or specificity of an identified test. [pmid: 10998135].
Fujisaku A, Frank M B, Neas B, et al. HLA-DQ gene complementation and other histocompatibility relationships in man with the anti-Ro/SSA autoantibody response of systemic lupus erythematosus. J Clin Invest. 1990;86(2):606-611. Not sensitivity or specificity of an identified test. [pmid: 1974555]. [pmcid: 296767].
Fujita K, Naito S, Okabe N, et al. Immunological studies in Crohn's disease. I. Association with HLA systems in the Japanese. J Clin Lab Immunol. 1984;14(2):99-102. Not sensitivity or specificity of an identified test. [pmid: 6611420].
Fukayama M, Koike M. So-called sclerosing hemangioma of the lung. An immunohistochemical, histochemical and ultrastructural study. Acta Pathologica Japonica. 1988;38(5):627-642. Not sensitivity or specificity of an identified test. [pmid: 2463730].
Fukuda K. Induction of tissue transglutaminase expression by propionate and n-butyrate in colon cancer cell lines. J Nutr Biochem. 1999;10(7):397-404. Not sensitivity or specificity of an identified test. [pmid: 15539315].
Fullen D R, Reed J A, Finnerty B, et al. S100A6 expression in fibrohistiocytic lesions. Journal of Cutaneous Pathology. 2001;28(5):229-234. Not sensitivity or specificity of an identified test. [pmid: 11493376].
Furuya Y, Lundmo P, Short A D, et al. The role of calcium, pH, and cell proliferation in the programmed (apoptotic) death of androgen-independent prostatic cancer cells induced by thapsigargin. Cancer Research. 1994;54(23):6167-6175. Not sensitivity or specificity of an identified test. [pmid: 7954463].
Gaboardi F, Perletti L, Cambie M, et al. Dermatitis herpetiformis and nephrotic syndrome. Clinical Nephrology. 1983;20(1):49-51. Not sensitivity or specificity of an identified test. [pmid: 6883819].
Gabrielli Maurizio, Cremonini Filippo, Fiore Giuseppe, et al. Association between migraine and Celiac disease: results from a preliminary case-control and therapeutic study. American Journal of Gastroenterology. 2003;98(3):625-629. Not sensitivity or specificity of an identified test. [pmid: 12650798].
Gale L, Wimalaratna H, Brotodiharjo A, et al. Down Syndrome is strongly associated with coeliac disease. Gut. 1997;40(4):492-496. Not sensitivity or specificity of an identified test. [pmid: 9176077]. [pmcid: 1027124].
Gallagher R B, Cervi P, Kelly J, et al. The subclass profile and complement activating potential of anti-alpha-gliadin antibodies in coeliac disease. Journal of Clinical & Laboratory Immunology. 1989;28(3):115-121. Not sensitivity or specificity of an identified test. [pmid: 2738909].
Gallagher R B, Feighery C, Weir D G, et al. Studies on the interaction between alpha-gliadin and HLA and T cell receptor molecules in coeliac disease. Clinical and Experimental Immunology. 1988;74(3):413-418. Not sensitivity or specificity of an identified test. [pmid: 3266119]. [pmcid: 1542030].
Gallagher R B, Kelly C P, Neville S, et al. Complement activation within the coeliac small intestine is localised to Brunner's glands. Gut. 1989;30(11):1568-1573. Not sensitivity or specificity of an identified test. [pmid: 2599443]. [pmcid: 1434320].
Gambelunghe G, Falorni A, Ghaderi M, et al. Microsatellite polymorphism of the MHC class I chain-related (MIC-A and MIC-B) genes marks the risk for autoimmune Addison's disease. J Clin Endocrinol Metab. 1999;84(10):3701-3707. Not sensitivity or specificity of an identified test. [pmid: 10523017].
Gambelunghe G, Forini F, Laureti S, et al. Increased risk for endocrine autoimmunity in Italian type 2 diabetic patients with GAD65 autoantibodies. Clin Endocrinol. 2000;52(5):565-573. Not sensitivity or specificity of an identified test.
Gambelunghe G, Ghaderi M, Cosentino A, et al. Association of MHC Class I chain-related A (MIC-A) gene polymorphism with Type I diabetes. Diabetologia. 2000;43(4):507-514. Not sensitivity or specificity of an identified test. [pmid: 10819246].
Gandolfi L, Catassi C, Garcia S, et al. Antiendomysial antibody test reliability in children with frequent diarrhea and malnutrition: is it celiac disease?. Journal of Pediatric Gastroenterology and Nutrition. 2001;33(4):483-487. Improper control group. [pmid: 11698768].
Gandolfi L, Pratesi R, Cordoba J C, et al. Prevalence of celiac disease among blood donors in Brazil. American Journal of Gastroenterology. 2000;95(3):689-692. Not sensitivity or specificity of an identified test. [pmid: 10710058].
Garcia Vilela E, De Lourdes, de Abreu, et al. Agreement between pathologists concerning assessment of intestinal biopsies from adult celiac disease patients. Gastroenterol Int. 2002;15(12):1-8. Improper control group.
Garcia-Buey L, Garcia-Monzon C, Rodriguez S, et al. Latent autoimmune hepatitis triggered during interferon therapy in patients with chronic hepatitis C. Gastroenterology. 1995;108(6):1770-1777. Not sensitivity or specificity of an identified test. [pmid: 7768382].
Gardas A, Bauer A, Rujner J, et al. An enzyme-linked immunosorbent assay for the detection of serum antibodies to alpha-gliadin. Pol J Immunol. 1994;19(1):49-60. Not sensitivity or specificity of an identified test.
Gardiner A J, Mutton K J, Walker Smith J A. A family study of coeliac disease. Aust Paediatr J. 1973;9(1):18-24. Not sensitivity or specificity of an identified test. [pmid: 4740140].
Garrote J A, Arranz E, Blanco-Quiros A. The HLA-DRB4 gene is present in half of the Spanish HLA-DQ2-negative celiac patients. Immunogenetics. 2000;51(12):1045-1046. Not sensitivity or specificity of an identified test. [pmid: 11061289].
Garrote J A, Sorell L, Alfonso P, et al. A novel visual immunoassay for coeliac disease screening. European Journal of Clinical Investigation. 1999;29(8):697-699. Not sensitivity or specificity of an identified test. [pmid: 10457154].
Garrote Jose A, Arranz Eduardo, Telleria Juan J, et al. TNF alpha and LT alpha gene polymorphisms as additional markers of celiac disease susceptibility in a DQ2-positive population. Immunogenetics. 2002;54(8):551-555. Not sensitivity or specificity of an identified test. [pmid: 12439617].
Gasbarrini Antonio, Ojetti Veronica, Cuoco Lucio, et al. Lack of endoscopic visualization of intestinal villi with the “immersion technique” in overt atrophic celiac disease. Gastrointestinal Endoscopy. 2003;57(3):348-351. Not sensitivity or specificity of an identified test. [pmid: 12612514].
Gasbarrini G, Miglio F, Serra M A, et al. Immunological studies of the jejunal mucosa in normal subjects and adult celiac patients. Digestion. 1974;10(2):122-128. Not sensitivity or specificity of an identified test. [pmid: 4601713].
Gasparini M, Brucato A, Riccobono S, et al. Congenital complete heart block (CCHB), cardiac Purkinje cells antibodies (CPCA) and HLA typing: Long term follow-up. New Trends Arrhythmias. 1991;7(4):969-974. Not sensitivity or specificity of an identified test.
Gasset A R, Richman A V, Frias J L. HLA antigens and keratoconus. Ann Ophthalmol. 1977;9(6):767-768. Not sensitivity or specificity of an identified test. [pmid: 911119].
Gaudry C A, Verderio E, Jones R A, et al. Tissue transglutaminase is an important player at the surface of human endothelial cells: evidence for its externalization and its colocalization with the beta(1) integrin. Experimental Cell Research. 1999;252(1):104-113. Not sensitivity or specificity of an identified test. [pmid: 10502403].
Gawkrodger D J, Blackwell J N, Gilmour H M, et al. Dermatitis herpetiformis: diagnosis, diet and demography. Gut. 1984;25(2):151-157. Not sensitivity or specificity of an identified test. [pmid: 6693042]. [pmcid: 1432259].
Gawkrodger D J, McDonald C, O'Mahony S, et al. Small intestinal function and dietary status in dermatitis herpetiformis. Gut. 1991;32(4):377-382. Not sensitivity or specificity of an identified test. [pmid: 2026337]. [pmcid: 1379074].
Gawkrodger D J, Sweeting V M, Edwards C R, et al. Male sex hormone status in dermatitis herpetiformis. British Journal of Dermatology. 1985;112(1):57-61. Not sensitivity or specificity of an identified test. [pmid: 3918554].
Gay G J, Delmotte J-S. Enteroscopy in small intestinal inflammatory diseases. Gastrointest Endosc Clin North Am. 1999;9(1):115-123. Not sensitivity or specificity of an identified test.
Gaze H, Rolles C, Signer E, et al. Premedication for jejunal biopsy in childhood using intravenous diazepam and metoclopramide. Archives of Disease in Childhood. 1974;49(4):322-324. Not sensitivity or specificity of an identified test. [pmid: 4830122].
Gazit E, Avigad S, Zfat Z, et al. The association of HL-A-B8 and childhood celiac disease in an Israeli population. Israel Journal of Medical Sciences. 1977;13(4):400-404. Not sensitivity or specificity of an identified test. [pmid: 873760].
Ge J, Hannestad K. A cytotoxic human hybridoma monoclonal antibody (TrJ6) defining an epitope expressed by HLA-DQ4 and -DQ5. Hum Immunol. 1994;39(2):106-112. Not sensitivity or specificity of an identified test. [pmid: 7533753].
Ge J, Bartnes K, Hannestad K. A human monoclonal hybridoma antibody (TrJ1) specific for HLA-DQ2. Tissue Antigens. 1993;41(2):81-85. Not sensitivity or specificity of an identified test. [pmid: 8386401].
Gebhard R L, Katz S I, Marks J. HL-A antigen type and small intestinal disease in dermatitis herpetiformis. Lancet. 1973;2(7832):760-762. Not sensitivity or specificity of an identified test. [pmid: 4126478].
Gebhard R L, Stone B G, Prigge W F. 3-Hydroxy-3-methylglutaryl coenzyme A reductase activity in the human gastrointestinal tract. Journal of Lipid Research. 1985;26(1):47-53. Not sensitivity or specificity of an identified test. [pmid: 3973513].
Geboes K, Ectors N, Desmet V J. Coeliac disease “anatomic pathology”. Acta Gastro-Enterologica Belgica. 1992;55(2):190-199. Not sensitivity or specificity of an identified test. [pmid: 1632139].
Geboes K, Ray M B, Rutgeerts P, et al. Morphological identification of alpha-I-antitrypsin in the human small intestine. Histopathology. 1982;6(1):55-60. Not sensitivity or specificity of an identified test. [pmid: 7035326].
Gebuhrer L, Adami N, Javaux F, et al. Sequence of a new HLA-DR4 allele with an unusual residue at position 88 that does not seem to affect T-cell allo recognition. Hum Immunol. 1996;51(1):60-62. Not sensitivity or specificity of an identified test. [pmid: 8911999].
Gedde-Dahl I I I, Spurkland A, Eriksen J A, et al. Memory T cells of a patient with follicular thyroid carcinoma recognize peptides derived from mutated p21 ras (Gln not <= Leu61). Int Immunol. 1992;4(11):1331-1337. Not sensitivity or specificity of an identified test. [pmid: 1282032].
Gelfand M D, Spiro H M, Herskovic T. Small intestine glutaminase deficiency in celiac disease. American Journal of Digestive Diseases. 1968;13(7):638-642. Not sensitivity or specificity of an identified test. [pmid: 5660603].
Gelmetti C, Bonifazi E, Cavalli R, et al. Dermatitis herpetiformis. Eur J Pediatr Dermatol. 1995;5(2):95-110. Not sensitivity or specificity of an identified test.
Gentile V, Davies P J, Baldini A. The human tissue transglutaminase gene maps on chromosome 20q12 by in situ fluorescence hybridization. Genomics. 1994;20(2):295-297. Not sensitivity or specificity of an identified test. [pmid: 7912692].
Gentile V, Porta R, Chiosi E, et al. tTGase/G alpha h protein expression inhibits adenylate cyclase activity in Balb-C 3T3 fibroblasts membranes. Biochimica Et Biophysica Acta. 1997;1357(1):115-122. Not sensitivity or specificity of an identified test. [pmid: 9202182].
Gentile V, Saydak M, Chiocca E A, et al. Isolation and characterization of cDNA clones to mouse macrophage and human endothelial cell tissue transglutaminases. J Biol Chem. 1991;266(1):478-483. Not sensitivity or specificity of an identified test. [pmid: 1670766].
Gentile V, Sepe C, Calvani M, et al. Tissue transglutaminase-catalyzed formation of high-molecular-weight aggregates in vitro is favored with long polyglutamine domains: a possible mechanism contributing to CAG-triplet diseases. Archives of Biochemistry and Biophysics. 1998;352(2):314-321. Not sensitivity or specificity of an identified test. [pmid: 9587422].
Gentile Vittorio, Violante Vittorio, D'Amico Bonifacio, et al. Tissue transglutaminase and coeliac disease pathogenesis: potential molecular mechanisms for other human diseases. Neurochemistry International. 2002;40(1):79-83. Not sensitivity or specificity of an identified test. [pmid: 11738474].
George E K, Hertzberger-ten Cate R, Suijlekom-Smit L W, et al. Juvenile chronic arthritis and coeliac disease in The Netherlands. Clinical and Experimental Rheumatology. 1996;14(5):571-575. Not sensitivity or specificity of an identified test. [pmid: 8913663].
George E K, Jansen T L T A, Mearin M L, et al. Epidemiology of celiac disease in the Netherlands. Journal of Pediatric Gastroenterology and Nutrition. 1997;24(5):S7-S9. Not sensitivity or specificity of an identified test. [pmid: 9161967].
George E K, Mearin M L, Bouquet J, et al. High frequency of celiac disease in Down syndrome. Journal of Pediatrics. 1996;128(4):555-557. Not sensitivity or specificity of an identified test. [pmid: 8618192].
George E K, Mearin M L, Bouquet J et al. Screening for coeliac disease in Dutch children with associated diseases. Acta paediatrica (Oslo, Norway : 1992)Supplement 1996;41252–53. Not sensitivity or specificity of an identified test
George E K, Mearin M L, Franken H C, et al. Twenty years of childhood coeliac disease in The Netherlands: a rapidly increasing incidence?. Gut. 1997;40(1):61-66. Not sensitivity or specificity of an identified test. [pmid: 9155577]. [pmcid: 1027009].
George E K, Mearin M L, van der V, et al. Low incidence of childhood celiac disease in The Netherlands. Pediatric Research. 1995;37(2):213-218. Not sensitivity or specificity of an identified test. [pmid: 7731760].
George M D, Vollberg T M, Floyd E E, et al. Regulation of transglutaminase type II by transforming growth factor-beta 1 in normal and transformed human epidermal keratinocytes. Journal of Biological Chemistry. 1990;265(19):11098-11104. Not sensitivity or specificity of an identified test. [pmid: 1972706].
Gerbase-DeLima M, Gallo C A, Daher S, et al. HLA antigens in asthmatic children. Pediatr Allergy Immunol. 1997;8(3):150-152. Not sensitivity or specificity of an identified test. [pmid: 9532256].
Gheorghe C, Gheorghe L, Constantinescu A, et al. The association between primary sclerosing cholangitis and adult celiac disease. Genomics. 2000;67(2):43-48. Not sensitivity or specificity of an identified test.
Gheorghe L, Gheorghe C, Aposteanu G, et al. Clinical spectrum of adult celiac disease in a referral center for Southern Romania. Associated disorders and short-term survival. Rom J Gastroenterol. 1996;5(4):223-228. Not sensitivity or specificity of an identified test.
Ghezzi A, Zaffaroni M. Neurological manifestations of gastrointestinal disorders, with particular reference to the differential diagnosis of multiple sclerosis. Neurological Sciences - Official Journal of the Italian Neurological Society and of the Italian Society of Clinical Neurophysiology. 2001;22(Suppl 2):s117-s122. Not sensitivity or specificity of an identified test. [pmid: 11794483].
Ghoos Y F, Vantrappen G R, Rutgeerts P J, et al. A mixed-triglyceride breath test for intraluminal fat digestive activity. Digestion. 1981;22(5):239-247. Not sensitivity or specificity of an identified test. [pmid: 6796447].
Giachino C, Rocci M P, De Libero G, et al. An alternative approach to the assessment of gamma delta T-cell clonality in celiac disease intestinal lesions through cDNA heteroduplex analysis of T-cell receptor VJ junctions. Human Immunology. 1994;40(4):303-311. Not sensitivity or specificity of an identified test. [pmid: 8002378].
Gianfrani Carmen, Troncone Riccardo, Mugione Patrizia, et al. Celiac disease association with CD8+ T cell responses: identification of a novel gliadin-derived HLA-A2-restricted epitope. Journal of Immunology (Baltimore, Md.- 1950). 2003;170(5):2719-2726. Not sensitivity or specificity of an identified test. [pmid: 12594302].
Giannotti A, Tiberio G, Castro M, et al. Coeliac disease in Williams syndrome. Journal of Medical Genetics. 2001;38(11):767-768. Not sensitivity or specificity of an identified test. [pmid: 11694549].
Gibran N S, Heimbach D M, Holbrook K A. Immunolocalization of FXIIIa+ dendritic cells in human burn wounds. Journal of Surgical Research. 1995;59(3):378-386. Not sensitivity or specificity of an identified test. [pmid: 7643597].
Gibran N S, Nickoloff B J, Holbrook K A. Ontogeny and characterization of factor XIIIa+ cells in developing human skin. Anatomy and Embryology. 1996;193(1):35-41. Not sensitivity or specificity of an identified test. [pmid: 8838494].
Gilchrist J M, Thompson G C, Medina J E. Markers of keratinocyte differentiation in snuff-induced leukoplakia. American Journal of Surgery. 1992;164(6):563-566. Not sensitivity or specificity of an identified test. [pmid: 1361105].
Gill S S, Heuman D M, Mihas A A. Small intestinal neoplasms. Journal of Clinical Gastroenterology. 2001;33(4):267-282. Not sensitivity or specificity of an identified test. [pmid: 11588539].
Gillberg R, Ahren C. Coeliac disease diagnosed by means of duodenoscopy and endoscopic duodenal biopsy. Scandinavian Journal of Gastroenterology. 1977;12(8):911-916. Not sensitivity or specificity of an identified test. [pmid: 605350].
Gillberg R, Dotevall G, Kastrup W, et al. Conventional malabsorption tests: do they detect the adult patient with villous atrophy?. Scandinavian Journal of Clinical and Laboratory Investigation. 1984;44(1):91-98. Not sensitivity or specificity of an identified test. [pmid: 6701455].
Gillberg R, Kastrup W, Mobacken H. Endoscopic duodenal biopsy compared with biopsy with the Watson capsule from the upper jejunum in patients with dermatitis herpetiformis. Scandinavian Journal of Gastroenterology. 1982;17(2):305-308. Not sensitivity or specificity of an identified test. [pmid: 7134857].
Gillberg R, Kastrup W, Mobacken H, et al. Gastric morphology and function in dermatitis herpetiformis and in coeliac disease. Scandinavian Journal of Gastroenterology. 1985;20(2):133-140. Not sensitivity or specificity of an identified test. [pmid: 3909375].
Gillet H, Ferguson A, Frier B. Coeliac disease often co-exists with Type 1 diabetes mellitus. Pract Diabetes Int. 1998;15(4):117-120. Not sensitivity or specificity of an identified test.
Gillett H R, Freeman H J. Prevalence of celiac disease in collagenous and lymphocytic colitis. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 2000;14(11):919-921. Not sensitivity or specificity of an identified test. [pmid: 11125181].
Gillett H R, Freeman H J. Serological testing in screening for adult celiac disease. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 1999;13(3):265-269. Not sensitivity or specificity of an identified test. [pmid: 10331939].
Gillett H R, Cauch-Dudek K, Jenny E, et al. Prevalence of IgA antibodies to endomysium and tissue transglutaminase in primary biliary cirrhosis. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 2000;14(8):672-675. Not sensitivity or specificity of an identified test. [pmid: 11185531].
Gillett P M, Israel D M. Tissue transglutaminase: does the key fit the celiac lock?. Journal of Pediatric Gastroenterology and Nutrition. 2000;30(2):222-223. Not sensitivity or specificity of an identified test. [pmid: 10697147].
Gillett P M, Gillett H R, Israel D M, et al. High prevalence of celiac disease in patients with type 1 diabetes detected by antibodies to endomysium and tissue transglutaminase. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 2001;15(5):297-301. Not sensitivity or specificity of an identified test. [pmid: 11381296].
Gillett P M, Gillett H R, Israel D M, et al. Increased prevalence of celiac disease in girls with Turner syndrome detected using antibodies to endomysium and tissue transglutaminase. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 2000;14(11):915-918. Not sensitivity or specificity of an identified test. [pmid: 11125180].
Giomi B, Cardinali C, Caproni M, et al. Immunological markers in dermatitis herpetiformis: Anti-endomysium and anti-transglutaminase in association with increased myeloperoxidase and eosinophil cationic protein serum levels. Int J Med Biol Environ. 2001;29(2):149-153. Not sensitivity or specificity of an identified test.
Giordano M, Bolognesi E, D'Alfonso S, et al. Linkage disequilibrium between intra-locus variants in the aminopeptidase n gene and test of their association with coeliac disease. Annals of Human Genetics. 1999;63(Pt 3):207-215. Not sensitivity or specificity of an identified test. [pmid: 10738533].
Giovannini C, Sanchez M, Straface E, et al. Induction of apoptosis in caco-2 cells by wheat gliadin peptides. Toxicology. 2000;145(1):63-71. Not sensitivity or specificity of an identified test. [pmid: 10771132].
Girdwood R H, Williams A W, McManus J P, et al. Jejunal biopsy in patients with malabsorptive disease. Scottish Medical Journal. 1966;11(10):343-355. Not sensitivity or specificity of an identified test. [pmid: 5972508].
Gjertsen H A, Lundin K E, Sollid L M, et al. T cells recognize a peptide derived from alpha-gliadin presented by the celiac disease-associated HLA-DQ (alpha 1*0501, beta 1*0201) heterodimer. Human Immunology. 1994;39(4):243-252. Not sensitivity or specificity of an identified test. [pmid: 7836060].
Gjertsen H A, Sollid L M, Ek J, et al. T cells from the peripheral blood of coeliac disease patients recognize gluten antigens when presented by HLA-DR, -DQ, or -DP molecules. Scandinavian Journal of Immunology. 1994;39(6):567-574. Not sensitivity or specificity of an identified test. [pmid: 8009173].
Gjone E, Oyri A. Protein-losing enteropathy in dermatitis herpetiformis. Scandinavian Journal of Gastroenterology. 1970;5(1):13-15. Not sensitivity or specificity of an identified test. [pmid: 5429862].
Glasgow J F, Corkey C W, Molla A. Critical assessment of small bowel biopsy in children. Archives of Disease in Childhood. 1979;54(8):604-608. Unable to extract data. [pmid: 507914].
Gobbi G, Ambrosetto P, Zaniboni M G, et al. Celiac disease, posterior cerebral calcifications and epilepsy. Brain & Development. 1992;14(1):23-29. Not sensitivity or specificity of an identified test. [pmid: 1590524].
Gobbi G, Bouquet F, Greco L, et al. Coeliac disease, epilepsy, and cerebral calcifications. The Italian Working Group on Coeliac Disease and Epilepsy. Lancet. 1992;340(8817):439-443. Not sensitivity or specificity of an identified test. [pmid: 1354781].
Godkin A, Jewell D. The pathogenesis of celiac disease. Gastroenterology. 1998;115(1):206-210. Not sensitivity or specificity of an identified test. [pmid: 9649476].
Godkin A J, Davenport M P, Willis A, et al. Use of complete eluted peptide sequence data from HLA-DR and -DQ molecules to predict T cell epitopes, and the influence of the nonbinding terminal regions of ligands in epitope selection. Journal of Immunology (Baltimore, Md.- 1950). 1998;161(2):850-858. Not sensitivity or specificity of an identified test. [pmid: 9670963].
Godkin A, Friede T, Davenport M, et al. Use of eluted peptide sequence data to identify the binding characteristics of peptides to the insulin-dependent diabetes susceptibility allele HLA-DQ8 (DQ 3.2). International Immunology. 1997;9(6):905-911. Not sensitivity or specificity of an identified test. [pmid: 9199974].
Godot V, Harraga S, Beurton I, et al. Resistance/susceptibility to Echinococcus multilocularis infection and cytokine profile in humans. II. Influence of the HLA B8, DR3, DQ2 haplotype. Clinical and Experimental Immunology. 2000;121(3):491-498. Not sensitivity or specificity of an identified test. [pmid: 10971516]. [pmcid: 1905739].
Goggins M, Kelleher D. Celiac disease and other nutrient related injuries to the gastrointestinal tract. American Journal of Gastroenterology. 1994;89(8 Suppl):S2-17. Not sensitivity or specificity of an identified test. [pmid: 8048412].
Goggins M, Whelan A, Kelleher D. The immunology of coeliac disease. Annales De Medecine Interne. 1996;147(1):40-48. Not sensitivity or specificity of an identified test. [pmid: 8763089].
Goldblum J R, Tuthill R J. CD34 and factor-XIIIa immunoreactivity in dermatofibrosarcoma protuberans and dermatofibroma. American Journal of Dermatopathology. 1997;19(2):147-153. Not sensitivity or specificity of an identified test. [pmid: 9129699].
Goldsmith L A. Human epidermal transglutaminase. Journal of Investigative Dermatology. 1983;80(Suppl):39s-41s. Not sensitivity or specificity of an identified test.
Goldstein F, Wirts C W, Salen G, et al. Diverticulosis of the small intestine. Clinical, bacteriologic, and metabolic observations in a group of seven patients. American Journal of Digestive Diseases. 1969;14(3):170-181. Not sensitivity or specificity of an identified test. [pmid: 4975349].
Goldstein N S, Underhill J. Morphologic features suggestive of gluten sensitivity in architecturally normal duodenal biopsy specimens. American Journal of Clinical Pathology. 2001;116(1):63-71. Improper control group. [pmid: 11447753].
Goldstein R, Sengar D P S. Comparative studies of the major histocompatibility complex in French Canadian and non-French Canadian Caucasians with systemic lupus erythematosus. Arthritis Rheum. 1993;36(8):1121-1127. Not sensitivity or specificity of an identified test. [pmid: 8343187].
Goldstein R, Moulds J M, Smith C D, et al. MHC studies of the primary antiphospholipid antibody syndrome and of antiphospholipid antibodies in systemic lupus erythematosus. J Rheumatol. 1996;23(7):1173-1179. Not sensitivity or specificity of an identified test. [pmid: 8823688].
Gomez J C, Selvaggio G S, Viola M, et al. Prevalence of celiac disease in Argentina: screening of an adult population in the La Plata area. American Journal of Gastroenterology. 2001;96(9):2700-2704. Not sensitivity or specificity of an identified test. [pmid: 11569698].
Gomez Juan C, Selvaggio Gisella, Pizarro Bibiana, et al. Value of a screening algorithm for celiac disease using tissue transglutaminase antibodies as first level in a population-based study. American Journal of Gastroenterology. 2002;97(11):2785-2790. Not sensitivity or specificity of an identified test. [pmid: 12425549].
Gonczi J, Skerritt J H, Mitchell J D. Differentiation of coeliac disease and other malabsorption diseases using specific serum antigliadin IgG subclass profiles and IgA1 levels. International Archives of Allergy and Immunology. 1992;98(4):377-385. Not sensitivity or specificity of an identified test. [pmid: 1422265].
Gonzalez D, Sugai E, Gomez J C, et al. Is it necessary to screen for celiac disease in postmenopausal osteoporotic women?. Calcified Tissue International. 2002;71(2):141-144. Not sensitivity or specificity of an identified test. [pmid: 12200648].
Gonzalez-Crussi F, Reyes-Mugica M. Cellular hemangiomas (“hemangioendotheliomas”) in infants. Light microscopic, immunohistochemical, and ultrastructural observations. American Journal of Surgical Pathology. 1991;15(8):769-778. Not sensitivity or specificity of an identified test. [pmid: 1676881].
Gonzalez-Trevin tilde, Yamamoto-Furusho J K, Cutin tilde, et al. HLA study on two Mexican mestizo families with autoimmune thyroid disease. Autoimmunity. 2002;35(4):265-269. Not sensitivity or specificity of an identified test. [pmid: 12482195].
Goodchild M C, Nelson R, Anderson C M. Cystic fibrosis and coeliac disease: coexistence in two children. Arch Dis Child. 1973;48(9):684-691. Not sensitivity or specificity of an identified test. [pmid: 4517654].
Goossens J F, Manechez D, Pommery N, et al. VIP potentiates retinoic-acid effect on tissue transglutaminase activity in human neuroblastoma, the SK-N-SH cells. Neuropeptides. 1993;24(2):99-103. Not sensitivity or specificity of an identified test. [pmid: 8096334].
Gorczyca Wojciech, Tsang Patricia, Liu Zach, et al. CD30-positive T-cell lymphomas co-expressing CD15: an immunohistochemical analysis. International Journal of Oncology. 2003;22(2):319-324. Not sensitivity or specificity of an identified test. [pmid: 12527929].
Gorkun O V, Veklich Y I, Weisel J W, et al. The conversion of fibrinogen to fibrin: recombinant fibrinogen typifies plasma fibrinogen. Blood. 1997;89(12):4407-4414. Not sensitivity or specificity of an identified test. [pmid: 9192765].
Gorski J, Niven M J, Sachs J A, et al. HLA-DR alpha, -DX alpha, and DR beta III gene association studies in DR3 individuals. Hum Immunol. 1987;20(4):273-278. Not sensitivity or specificity of an identified test. [pmid: 2893780].
Gorza L, Menabo R, Di Lisa F, et al. Troponin T cross-linking in human apoptotic cardiomyocytes. American Journal of Pathology. 1997;150(6):2087-2097. Not sensitivity or specificity of an identified test. [pmid: 9176400]. [pmcid: 1858314].
Gorza L, Menabo R, Vitadello M, et al. Cardiomyocyte troponin T immunoreactivity is modified by cross- linking resulting from intracellular calcium overload. Circulation. 1996;93(10):1896-1904. Not sensitivity or specificity of an identified test. [pmid: 8635269].
Gosiewska A, Yi C F, Blanc-Brude O, et al. Characterization of a macrophage-based system for studying the activation of latent TGF-beta. Methods in Cell Science - an Official Journal of the Society for in Vitro Biology. 1999;21(1):47-56. Not sensitivity or specificity of an identified test. [pmid: 10733258].
Gottardis M M, Lamph W W, Shalinsky D R, et al. The efficacy of 9-cis retinoic acid in experimental models of cancer. Breast Cancer Research and Treatment. 1996;38(1):85-96. Not sensitivity or specificity of an identified test. [pmid: 8825126].
Gottschalk J, Jautzke G, Schreiner C. Epithelial and melanoma antigens in gliosarcoma. An immunohistochemical study. Pathology, Research and Practice. 1992;188(12):182-190. Not sensitivity or specificity of an identified test. [pmid: 1594490].
Gottschalk J, Jautzke G, Marzheuser-Brands S, et al. Factor XIIIa immunoreactivity in primary and secondary tumours of the meninges. Zentralblatt Fur Pathologie. 1993;139(45):343-349. Not sensitivity or specificity of an identified test. [pmid: 7907501].
Goulet O, Kedinger M, Brousse N, et al. Intractable diarrhea of infancy with epithelial and basement membrane abnormalities. Journal of Pediatrics. 1995;127(2):212-219. Not sensitivity or specificity of an identified test. [pmid: 7636644].
Goulston K, Bhanthumnavin K, Harrison D. Investigation of steatorrhoea. Medical Journal of Australia. 1968;2(11):462-466. Not sensitivity or specificity of an identified test. [pmid: 5681222].
Grabarek Jerzy, Ardelt Barbara, Kunicki Jan, et al. Detection of in situ activation of transglutaminase during apoptosis: correlation with the cell cycle phase by multiparameter flow and laser scanning cytometry. Cytometry - the Journal of the Society for Analytical Cytology. 2002;49(2):83-89. Not sensitivity or specificity of an identified test. [pmid: 12357464].
Graff Ronald D, Picher Maryse, Lee Greta M. Extracellular nucleotides, cartilage stress, and calcium crystal formation. Current Opinion in Rheumatology. 2003;15(3):315-320. Not sensitivity or specificity of an identified test. [pmid: 12707587].
Graham J, Kockum I, Sanjeevi C B, et al. Negative association between type 1 diabetes and HLA DQB1*0602-DQA1*0102 is attenuated with age at onset. Eur J Immunogenet. 1999;26(23):117-127. Not sensitivity or specificity of an identified test. [pmid: 10331157].
Graham Jinko, Hagopian William A, Kockum Ingrid, et al. Genetic effects on age-dependent onset and islet cell autoantibody markers in type 1 diabetes. Diabetes. 2002;51(5):1346-1355. Not sensitivity or specificity of an identified test. [pmid: 11978629].
Grainger D J, Frow E K. Thrombospondin 1 does not activate transforming growth factor beta1 in a chemically defined system or in smooth-muscle-cell cultures. Biochem J. 2000;350(1):291-298. Not sensitivity or specificity of an identified test. [pmid: 10926856]. [pmcid: 1221254].
Granados J, Vargas-Alarcon G, Drenkard C, et al. Relationship of anticardiolipin antibodies and antiphospholipid syndrome to HLA-DR7 in Mexican patients with systemic lupus erythematosus (SLE). Lupus. 1997;6(1):57-62. Not sensitivity or specificity of an identified test. [pmid: 9116720].
Granditsch G, Deutsch J, Tsarmaklis G, et al. Exposure to X-rays during small bowel biopsies in children. European Journal of Pediatrics. 1981;137(2):165-169. Not sensitivity or specificity of an identified test. [pmid: 7308227].
Granditsch G, Ludwig H, Polymenidis Z, et al. Letter: Coeliac disease and HL-A8. Lancet. 1973;2(7834):908-909. Not sensitivity or specificity of an identified test. [pmid: 4126943].
Grando S A, Horton R M, Mauro T M, et al. Activation of keratinocyte nicotinic cholinergic receptors stimulates calcium influx and enhances cell differentiation. Journal of Investigative Dermatology. 1996;107(3):412-418. Not sensitivity or specificity of an identified test. [pmid: 8751979].
Granot E, Korman S M, Sallon S, et al. “Early” vs. “late” diagnosis of celiac disease in two ethnic groups living in the same geographic area. Israel Journal of Medical Sciences. 1994;30(4):271-275. Not sensitivity or specificity of an identified test. [pmid: 8175328].
Gravinghoff J, Huetter H J. The activities of alanine aminopeptidase, leucine aminopeptidase, proline dipeptidase and prolyl dipeptidase in the mucosa of the small intestine. Investigations on normal children and patients with the malabsorption syndrome. European Journal of Pediatrics. 1977;127(1):57-62. Not sensitivity or specificity of an identified test. [pmid: 606559].
Gray M H, Smoller B R, McNutt N S, et al. Immunohistochemical demonstration of factor XIIIa expression in neurofibromas. A practical means of differentiating these tumors from neurotized melanocytic nevi and schwannomas. Archives of Dermatology. 1990;126(4):472-476. Not sensitivity or specificity of an identified test. [pmid: 2146926].
Gray M H, Trimble C L, Zirn J, et al. Relationship of factor XIIIa-positive dermal dendrocytes to Kaposi's sarcoma. Archives of Pathology & Laboratory Medicine. 1991;115(8):791-796. Not sensitivity or specificity of an identified test. [pmid: 1713758].
Greco L, Babron M C, Corazza G R et al. Existence of a genetic risk factor on chromosome 5q in Italian Coeliac disease families. Ann Hum Genet 2001;-(1):35–41. Not sensitivity or specificity of an identified test
Greco L, Corazza G, Babron M C, et al. Genome search in celiac disease. American Journal of Human Genetics. 1998;62(3):669-675. Not sensitivity or specificity of an identified test. [pmid: 9497251]. [pmcid: 1376948].
Greco L, D'Adamo G, Truscelli A, et al. Intestinal permeability after single dose gluten challenge in coeliac disease. Archives of Disease in Childhood. 1991;66(7):870-872. Not sensitivity or specificity of an identified test. [pmid: 1863103].
Greco L, Percopo S, Clot F, et al. Lack of correlation between genotype and phenotype in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1998;26(3):286-290. Not sensitivity or specificity of an identified test. [pmid: 9523863].
Greco L, Romino R, Coto I, et al. The first large population based twin study of coeliac disease. Gut. 2002;50(5):624-628. Not sensitivity or specificity of an identified test. [pmid: 11950806]. [pmcid: 1773191].
Greco L, Troncone R, De Vizia B, et al. Discriminant analysis for the diagnosis of childhood celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1987;6(4):538-542. Improper control group. [pmid: 3430260].
Green Peter H R, Jabri Bana. Coeliac disease. Lancet. 2003;362(9381):383-391. Not sensitivity or specificity of an identified test. [pmid: 14615111].
Green J R, Chiew M K, Low H C, et al. The association between HLA antigens and the presence of certain diseases. Statistics in Medicine. 1983;2(1):79-85. Not sensitivity or specificity of an identified test. [pmid: 6648122].
Green J R, Goble H L, Edwards C R, et al. Reversible insensitivity to androgens in men with untreated gluten enteropathy. Lancet. 1977;1(8006):280-282. Not sensitivity or specificity of an identified test. [pmid: 64806].
Green P H R, Stavropoulos S N, Panagi S G, et al. Characteristics of adult celiac disease in the USA: results of a national survey. American Journal of Gastroenterology. 2001;96(1):126-131. Not sensitivity or specificity of an identified test. [pmid: 11197241].
Green P H, Shane E, Rotterdam H, et al. Significance of unsuspected celiac disease detected at endoscopy. Gastrointestinal Endoscopy. 2000;51(1):60-65. Not sensitivity or specificity of an identified test. [pmid: 10625798].
Greenberg C S, Achyuthan K E, Borowitz M J, et al. The transglutaminase in vascular cells and tissues could provide an alternate pathway for fibrin stabilization. Blood. 1987;70(3):702-709. Not sensitivity or specificity of an identified test. [pmid: 2887223].
Greenberg C S, Birckbichler P J, Rice R H. Transglutaminases: multifunctional cross-linking enzymes that stabilize tissues. Faseb Journal - Official Publication of the Federation of American Societies for Experimental Biology. 1991;5(15):3071-3077. Not sensitivity or specificity of an identified test.
Greenberg D A, Lange K L. A maximum likelihood test of the two locus model for coeliac disease. American Journal of Medical Genetics. 1982;12(1):75-82. Not sensitivity or specificity of an identified test. [pmid: 7091198].
Greenberg D A, Rotter J I. Two locus models for gluten sensitive enteropathy: population genetic considerations. American Journal of Medical Genetics. 1981;8(2):205-214. Not sensitivity or specificity of an identified test. [pmid: 7282774].
Greenberg D A, Hodge S E, Rotter J I. Evidence for recessive and against dominant inheritance at the HLA-“linked” locus in coeliac disease. American Journal of Human Genetics. 1982;34(2):263-277. Not sensitivity or specificity of an identified test. [pmid: 6951410]. [pmcid: 1685281].
Greenhouse J P, Monier-Williams M. Geophysical monitoring of ground water contamination around waste disposal sites. Ground Water Monit Rev. 1985;5(4):63-69. Not sensitivity or specificity of an identified test.
Greenwald A J, Johnson D S, Oskvig R M, et al. Alpha-1-antitrypsin deficiency, emphysema, cirrhosis, and intestinal mucosal atrophy. Jama - the Journal of the American Medical Association. 1975;231(3):273-276. Not sensitivity or specificity of an identified test. [pmid: 1078583].
Grefte J M, Bouman J G, Grond J, et al. Slow and incomplete histological and functional recovery in adult gluten sensitive enteropathy. Journal of Clinical Pathology. 1988;41(8):886-891. Not sensitivity or specificity of an identified test. [pmid: 3170777]. [pmcid: 1141622].
Grehn S, Fridell K, Lilliecreutz M, et al. Dietary habits of Swedish adult coeliac patients treated by a gluten-free diet for 10 years. Scand J Nutr Naringsforsk. 2001;45(4):178-182. Not sensitivity or specificity of an identified test.
Grenard P, Bates M K, Aeschlimann D. Evolution of transglutaminase genes: identification of a transglutaminase gene cluster on human chromosome 15q15. Structure of the gene encoding transglutaminase X and a novel gene family member, transglutaminase Z. Journal of Biological Chemistry. 2001;276(35):33066-33078. Not sensitivity or specificity of an identified test. [pmid: 11390390].
Grierson A J, Johnson G V, Miller C C. Three different human tau isoforms and rat neurofilament light, middle and heavy chain proteins are cellular substrates for transglutaminase. Neuroscience Letters. 2001;298(1):9-12. Not sensitivity or specificity of an identified test. [pmid: 11154823].
Griffin Martin, Casadio Rita, Bergamini Carlo M. Transglutaminases: nature's biological glues. Biochemical Journal. 2002;368(Pt 2):377-396. Not sensitivity or specificity of an identified test. [pmid: 12366374]. [pmcid: 1223021].
Griffiths C E, Barrison I G, Leonard J N, et al. Preferential activation of CD4 T lymphocytes in the lamina propria of gluten-sensitive enteropathy. Clinical and Experimental Immunology. 1988;72(2):280-283. Not sensitivity or specificity of an identified test. [pmid: 3261663]. [pmcid: 1541551].
Grigoriev M Y, Suspitsin E N, Togo A V, et al. Tissue transglutaminase expression in breast carcinomas. Journal of Experimental & Clinical Cancer Research - Cr. 2001;20(2):265-268. Not sensitivity or specificity of an identified test. [pmid: 11484985].
Grillo R, Petronzelli F, Ferrante P, et al. Unusual HLA typing in celiac disease. Disease Markers. 1996;13(1):61-64. Not sensitivity or specificity of an identified test. [pmid: 8875120].
Grodzinsky E. Screening for coeliac disease in apparently healthy blood donors. Acta paediatrica (Oslo, Norway : 1992).Supplement 1996;41236–38. Improper control group
Grodzinsky E, Franzen L, Hed J, et al. High prevalence of celiac disease in healthy adults revealed by antigliadin antibodies. Annals of Allergy. 1992;69(1):66-70. Improper control group. [pmid: 1626762].
Grodzinsky E, Hed J, Skogh T. IgA antiendomysium antibodies have a high positive predictive value for celiac disease in asymptomatic patients. Allergy. 1994;49(8):593-597. Improper control group. [pmid: 7653735].
Grodzinsky E, Hed J, Lieden G, et al. Presence of IgA and IgG antigliadin antibodies in healthy adults as measured by micro-ELISA. Effect of various cutoff levels on specificity and sensitivity when diagnosing coeliac disease. International Archives of Allergy and Applied Immunology. 1990;92(2):119-123. Improper control group. [pmid: 2242925].
Grodzinsky E, Ivarsson A, Juto P, et al. New automated immunoassay measuring immunoglobulin A antigliadin antibodies for prediction of celiac disease in childhood. Clinical and Diagnostic Laboratory Immunology. 2001;8(3):564-570. Improper control group. [pmid: 11329459]. [pmcid: 96102].
Grodzinsky E, Jansson G, Skogh T, et al. Anti-endomysium and anti-gliadin antibodies as serological markers for coeliac disease in childhood: a clinical study to develop a practical routine. Acta Paediatrica (Oslo, Norway - 1992). 1995;84(3):294-298. Improper control group. [pmid: 7780251].
Groisman G M, Sabo E, Meir A, et al. Enterocyte apoptosis and proliferation are increased in microvillous inclusion disease (familial microvillous atrophy). Human Pathology. 2000;31(11):1404-1410. Not sensitivity or specificity of an identified test. [pmid: 11112216].
Groisman Gabriel M, Amar Mary, Livne Erella. CD10: a valuable tool for the light microscopic diagnosis of microvillous inclusion disease (familial microvillous atrophy). American Journal of Surgical Pathology. 2002;26(7):902-907. Not sensitivity or specificity of an identified test. [pmid: 12131157].
Groll A. Symposium on diarrhea. 3. Investigation of chronic diarrhea. Canadian Medical Association Journal. 1977;116(7):742-744. Not sensitivity or specificity of an identified test. [pmid: 191173]. [pmcid: 1879444].
Groll A, Candy D C, Preece M A, et al. Short stature as the primary manifestation of coeliac disease. Lancet. 1980;2(8204):1097-1099. Not sensitivity or specificity of an identified test. [pmid: 6107721].
Gross Stephane R, Balklava Zita, Griffin Martin. Importance of tissue transglutaminase in repair of extracellular matrices and cell death of dermal fibroblasts after exposure to a solarium ultraviolet A source. Journal of Investigative Dermatology. 2003;121(2):412-423. Not sensitivity or specificity of an identified test. [pmid: 12880435].
Grunewald J, Olerup O, Persson U, et al. T-cell receptor variable region gene usage by CD4sup + and CD8sup + T cells in bronchoalveolar lavage fluid and peripheral blood of sarcoidosis patients. Proc Natl Acad Sci U S A. 1994;91(11):4965-4969. Not sensitivity or specificity of an identified test. [pmid: 7910965]. [pmcid: 43910].
Grunewald J, Shigematsu M, Nagai S, et al. T-cell receptor V gene expression in HLA-typed Japanese patients with pulmonary sarcoidosis. Am J Respir Crit Care Med. 1995;151(1):151-156. Not sensitivity or specificity of an identified test. [pmid: 7812546].
Gryboski J. False security of a gluten-free diet. American Journal of Diseases of Children (1960). 1981;135(2):110-111. Not sensitivity or specificity of an identified test. [pmid: 7468541].
Grzybowski J, Antos M, Sakiel S, et al. Antidietary antigen antibodies in the sera of patients with burns as a potential marker of gut mucosa integrity failure. Journal of Burn Care & Rehabilitation. 1992;13(2 Pt 1):194-197. Not sensitivity or specificity of an identified test. [pmid: 1587916].
Guadiz G, Sporn L A, Simpson-Haidaris P J. Thrombin cleavage-independent deposition of fibrinogen in extracellular matrices. Blood. 1997;90(7):2644-2653. Not sensitivity or specificity of an identified test. [pmid: 9326231].
Guandalini S. Celiac disease in the new world. Journal of Pediatric Gastroenterology and Nutrition. 2000;31(4):362-364. Not sensitivity or specificity of an identified test. [pmid: 11045848].
Guandalini S, Ventura A, Ansaldi N, et al. Diagnosis of coeliac disease: time for a change?. Archives of Disease in Childhood. 1989;64(9):1320-1324. Not sensitivity or specificity of an identified test. [pmid: 2817956].
Guarino A, Spagnuolo M I, Russo S, et al. Etiology and risk factors of severe and protracted diarrhea. Journal of Pediatric Gastroenterology and Nutrition. 1995;20(2):173-178. Not sensitivity or specificity of an identified test. [pmid: 7714682].
Guariso G, Messina C, Gazzola M V, et al. Transient erythoblastopenia in coeliac disease. Haematologica. 2001;86(8):E23. Not sensitivity or specificity of an identified test. [pmid: 11524273].
Guglielmino C R, De Silvestri A, Martinetti M. HLA class I and II genes in relation to the genetic structure and epidemiology of an Italian province. Experimental and Clinical Immunogenetics. 1997;14(2):149-159. Not sensitivity or specificity of an identified test. [pmid: 9395891].
Guiraldes E, Gutierrez C, Castillo C. Letter: Coeliac disease. Medical Journal of Australia. 1975;1(10):322. Not sensitivity or specificity of an identified test. [pmid: 1128350].
Guix M, Skinner J M, Whitehead R. Morphometric electron and light microscope analysis of lymphoid cells in coeliac disease. Scandinavian Journal of Gastroenterology. 1979;14(3):261-265. Not sensitivity or specificity of an identified test. [pmid: 375374].
Guix M, Skinner J M, Whitehead R. Ultrastructural analysis of plasma cells in celiac patients. Gut. 1979;20(6):504-508. Not sensitivity or specificity of an identified test. [pmid: 468077]. [pmcid: 1412443].
Gumurdulu Derya, Zeren E, Handan Cagle, et al. Specificity of MOC-31 and HBME-1 immunohistochemistry in the differential diagnosis of adenocarcinoma and malignant mesothelioma: a study on environmental malignant mesothelioma cases from Turkish villages. Pathology Oncology Research - Por. 2003;8(3):188-193. Not sensitivity or specificity of an identified test.
Gupta M, Nikitina-Zake L, Landin-Olsson M, et al. Coxsackie virus B antibodies are increased in HLA DR3-MICA5.1 positive type 1 diabetes patients in the Linkoping region of Sweden. Hum Immunol. 2003;64(9):874-879. Not sensitivity or specificity of an identified test. [pmid: 12941547].
Gupta M, Nikitina-Zake L, Zarghami M, et al. Association between the transmembrane region polymorphism of MHC class I chain related gene-A and type 1 diabetes mellitus in Sweden. Hum Immunol. 2003;64(5):553-561. Not sensitivity or specificity of an identified test. [pmid: 12691706].
Gupta M, Tandon N, Shtauvere-Brameus A, et al. ICA12 autoantibodies are associated with Non-DR3/Non-DR4 in patients with latent autoimmune diabetes in adults from Northern India. Ann New York Acad Sci. 2002;958(-):329-332. Not sensitivity or specificity of an identified test. [pmid: 12021135].
Gupte S. Changing concepts in celiac disease. Jk Science. 2001;3(3):103-104. Not sensitivity or specificity of an identified test.
Guvenc cedil, Kaymakog caron, Gurel N, et al. The prevalence of manifest and latent celiac disease in type 1 diabetes mellitus. Turk J Gastroenterol. 2002;13(2):103-107. Not sensitivity or specificity of an identified test. [pmid: 16378286].
Guzman J, Bross K J, Wurtemberger G, et al. Immunocytology in malignant pleural mesothelioma. Expression of tumor markers and distribution of lymphocyte subsets. Chest. 1989;95(3):590-595. Not sensitivity or specificity of an identified test. [pmid: 2646076].
Haas L, Petit-Phar M, Terzidis H, et al. IgA subclass distribution of IgA anti-gliadin antibodies in feces of patients with coeliac disease. Advances in Experimental Medicine and Biology. 1995;371b:1349-1353. Not sensitivity or specificity of an identified test. [pmid: 7502815].
Habior Andrzej, Lewartowska Aleksandra, Orlowska Janina, et al. Association of coeliac disease with primary biliary cirrhosis in Poland. European Journal of Gastroenterology & Hepatology. 2003;15(2):159-164. Not sensitivity or specificity of an identified test. [pmid: 12560760].
Hadjivassiliou M, Boscolo S, Davies-Jones G A B, et al. The humoral response in the pathogenesis of gluten ataxia. Neurology. 2002;58(8):1221-1226. Not sensitivity or specificity of an identified test. [pmid: 11971090].
Hadjivassiliou M, Chattopadhyay A K, Davies-Jones G A B, et al. Neuromuscular disorder as a presenting feature of coeliac disease. J Neurol Neurosurg Psychiatry. 1997;63(6):770-775. Not sensitivity or specificity of an identified test. [pmid: 9416814].
Hadjivassiliou M, Davies-Jones G A B, Sanders D S, et al. Dietary treatment of gluten ataxia. Journal of Neurology, Neurosurgery, and Psychiatry. 2003;74(9):1221-1224. Not sensitivity or specificity of an identified test. [pmid: 12933922].
Hadjivassiliou M, Gibson A, Davies-Jones G A, et al. Does cryptic gluten sensitivity play a part in neurological illness?. Lancet. 1996;347(8998):369-371. Not sensitivity or specificity of an identified test. [pmid: 8598704].
Hadjivassiliou M, Grunewald R A, Davies-Jones G A B. Gluten sensitivity: A many headed hydra. Br Med J. 1999;318(7200):1710-1711. Not sensitivity or specificity of an identified test. [pmid: 10381684]. [pmcid: 1116063].
Hadjivassiliou M, Grunewald R A, Davies-Jones G A B. Gluten sensitivity as a neurological illness. J Neurol Neurosurg Psychiatry. 2002;72(5):560-563. Not sensitivity or specificity of an identified test. [pmid: 11971034].
Hadjivassiliou M, Grunewald R A, Chattopadhyay A K, et al. Clinical, radiological, neurophysiological, and neuropathological characteristics of gluten ataxia. Lancet. 1998;352(9140):1582-1585. Not sensitivity or specificity of an identified test. [pmid: 9843103].
Hadjivassiliou Marios, Grunewald Richard, Sharrack Basil et al. Gluten ataxia in perspective: epidemiology, genetic susceptibility and clinical characteristics. Brain 2003;A Journal of Neurology; 126(Pt 3):685–691. Not sensitivity or specificity of an identified test
Hadziselimovic F, Emmons L R, Schaub U, et al. Occurrence of large granular lymphocytes and natural killer cells in the epithelium of the gut distinguishes two different coeliac diseases. Gut. 1992;33(6):767-772. Not sensitivity or specificity of an identified test. [pmid: 1624157]. [pmcid: 1379333].
Hafeez A, Ali S, Hassan M. An audit of pediatric upper gastrointestinal endoscopies. J Coll Phys Surg Pak. 2000;10(1):13-15. Not sensitivity or specificity of an identified test.
Hafstrom I, Ringertz B, Spangberg A, et al. A vegan diet free of gluten improves the signs and symptoms of rheumatoid arthritis: The effects on arthritis correlate with a reduction in antibodies to food antigens. Rheumatology (Uk). 2001;40(10):1175-1179. Not sensitivity or specificity of an identified test.
Haga P. Plasma ferritin concentrations in preterm infants in cord blood and during the early anaemia of prematurity. Acta Paediatrica Scandinavica. 1980;69(5):637-641. Not sensitivity or specificity of an identified test. [pmid: 7234384].
Hager H, Gliemann J, Hamilton-Dutoit S, et al. Developmental regulation of tissue transglutaminase during human placentation and expression in neoplastic trophoblast. Journal of Pathology. 1997;181(1):106-110. Not sensitivity or specificity of an identified test. [pmid: 9072011].
Hager H, Jensen P H, Hamilton-Dutoit S, et al. Expression of tissue transglutaminase in human bladder carcinoma. Journal of Pathology. 1997;183(4):398-403. Not sensitivity or specificity of an identified test. [pmid: 9496255].
Hagopian W A, Sanjeevi C B, Kockum I, et al. Glutamate decarboxylase-, insulin-, and islet cell-antibodies and HLA typing to detect diabetes in a general population-based study of Swedish children. Journal of Clinical Investigation. 1995;95(4):1505-1511. Not sensitivity or specificity of an identified test. [pmid: 7706455]. [pmcid: 295633].
Hahn-Zoric M, Hytonen A M, Hanson L A, et al. Association of -1087 IL10 and -308 TNFA gene polymorphisms with serological markers of coeliac disease. J Clin Immunol. 2003;23(4):291-296. Not sensitivity or specificity of an identified test. [pmid: 12959221].
Hahnel A C, Eddy E M. Cell surface markers of mouse primordial germ cells defined by two monoclonal antibodies. Gamete Res. 1986;15(1):25-34. Not sensitivity or specificity of an identified test.
Hahnel A C, Eddy E M. The distribution of two cell surface determinants of mouse embryonal carcinoma and early embryonic cells. J Reprod Immunol. 1987;10(2):89-110. Not sensitivity or specificity of an identified test. [pmid: 3598980].
Hajjar E T, Vincenti F, Salti I S. Gluten induced enteropathy. Osteomalacia as its principal manifestation. Arch Intern Med 1974;134(3):565-566. Not sensitivity or specificity of an identified test.
Hakeem V, Fifield R, al Bayaty H F, et al. Salivary IgA antigliadin antibody as a marker for coeliac disease. Archives of Disease in Childhood. 1992;67(6):724-727. Test-specific exclusio. [pmid: 1626993].
Hall M A, Lanchbury J S, Ciclitira P J. HLA class II region genes and susceptibility to dermatitis herpetiformis: DPB1 and TAP2 associations are secondary to those of the DQ subregion. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1996;23(4):285-296. Not sensitivity or specificity of an identified test. [pmid: 8858285].
Hall M A, Lanchbury J S, Bolsover W J, et al. Celiac disease is associated with an extended HLA-DR3 haplotype which includes HLA-DPw1. Hum Immunol. 1990;27(3):220-228. Not sensitivity or specificity of an identified test. [pmid: 1971269].
Hall M A, Lanchbury J S, Bolsover W J, et al. HLA association with dermatitis herpetiformis is accounted for by a cis or transassociated DQ heterodimer. Gut. 1991;32(5):487-490. Not sensitivity or specificity of an identified test. [pmid: 1674926]. [pmcid: 1378922].
Hall M A, Lanchbury J S, Lee J S, et al. HLA-DQ2 second-domain polymorphisms may explain increased trans-associated risk in celiac disease and dermatitis herpetiformis. Human Immunology. 1993;38(4):284-292. Improper control group. [pmid: 8138424].
Hall M A, Lanchbury J S, Sturgess R P, et al. TCR Vbeta usage in peripheral blood and small intestinal bipsies of treated and untreated coeliac disease patients. Eur J Immunogenet. 1992;19(6):439. Not sensitivity or specificity of an identified test.
Hall P A, d'Ardenne A J, Stansfeld A G. Paraffin section immunohistochemistry. I. Non-Hodgkin's lymphoma. Histopathology. 1988;13(2):149-160. Not sensitivity or specificity of an identified test. [pmid: 3262564].
Hall R P. Dermatitis herpetiformis and the mucosal immune response. Journal of Autoimmunity. 1991;4(1):47-58. Not sensitivity or specificity of an identified test. [pmid: 2031663].
Hall R P. The pathogenesis of dermatitis herpetiformis: recent advances. Journal of the American Academy of Dermatology. 1987;16(6):1129-1144. Not sensitivity or specificity of an identified test. [pmid: 3316319].
Hall R P, Waldbauer G V. Characterization of the mucosal immune response to dietary antigens in patients with dermatitis herpetiformis. Journal of Investigative Dermatology. 1988;90(5):658-663. Not sensitivity or specificity of an identified test. [pmid: 3258898].
Hall R P, Lawley T J, Katz S I. Dermatitis herpetiformis. Springer Seminars in Immunopathology. 1981;4(1):33-43. Not sensitivity or specificity of an identified test. [pmid: 7022720].
Hall R P, Owen S, Smith A, et al. TCR Vbeta expression in the small bowel of patients with dermatitis herpetiformis and gluten sensitive enteropathy. Limited expression in dermatitis herpetiformis and treated asymptomatic gluten sensitive enteropathy. Experimental Dermatology. 2000;9(4):275-282. Not sensitivity or specificity of an identified test. [pmid: 10949550].
Hall R P, Ward F E, Wenstrup R J. An HLA class II region restriction fragment length polymorphism (RFLP) in patients with dermatitis herpetiformis: association with HLA-DP phenotype. Journal of Investigative Dermatology. 1990;95(2):172-177. Not sensitivity or specificity of an identified test. [pmid: 1974277].
Hallert C, Granno C, Grant C, et al. Quality of life of adult coeliac patients treated for 10 years. Scandinavian Journal of Gastroenterology. 1998;33(9):933-938. Not sensitivity or specificity of an identified test. [pmid: 9759948].
Hallert C, Tobiasson P, Walan A. Serum folate determinations in tracing adult coeliacs. Scandinavian Journal of Gastroenterology. 1981;16(2):263-267. Not sensitivity or specificity of an identified test. [pmid: 7313538].
Hallgren J, Knutson F, Lavo B, et al. Increased mucosal synthesis of rheumatoid factor (RF) in coeliac disease. Clinical and Experimental Immunology. 1996;103(1):94-98. Not sensitivity or specificity of an identified test. [pmid: 8565295]. [pmcid: 2200328].
Hallgren R, Colombel J F, Dahl R, et al. Neutrophil and eosinophil involvement of the small bowel in patients with celiac disease and Crohn's disease: studies on the secretion rate and immunohistochemical localization of granulocyte granule constituents. American Journal of Medicine. 1989;86(1):56-64. Not sensitivity or specificity of an identified test. [pmid: 2535919].
Halsted C H, Reisenauer A M, Romero J J. Jejunal perfusion of simple and conjugated folates in celiac sprue. J Clin Invest. 1977;59(5):933-940. Not sensitivity or specificity of an identified test. [pmid: 856874]. [pmcid: 372301].
Halstensen T S, Hvatum M, Scott H, et al. Association of subepithelial deposition of activated complement and immunoglobulin G and M response to gluten in celiac disease. Gastroenterology. 1992;102(3):751-759. Not sensitivity or specificity of an identified test. [pmid: 1537512].
Halstensen T S, Scott H, Brandtzaeg P. Human CD8+ intraepithelial T lymphocytes are mainly CD45RA-RB+ and show increased co-expression of CD45R0 in celiac disease. European Journal of Immunology. 1990;20(8):1825-1830. Not sensitivity or specificity of an identified test. [pmid: 2145168].
Halstensen T S, Scott H, Fausa O, et al. Gluten stimulation of coeliac mucosa in vitro induces activation (CD25) of lamina propria CD4+ T cells and macrophages but no crypt-cell hyperplasia. Scandinavian Journal of Immunology. 1993;38(6):581-590. Not sensitivity or specificity of an identified test. [pmid: 7902998].
Halter S A, Greene H L, Helinek G. Gluten-sensitive enteropathy: sequence of villous regrowth as viewed by scanning electron microscopy. Human Pathology. 1982;13(9):811-818. Not sensitivity or specificity of an identified test. [pmid: 7106746].
Halter S A, Greene H L, Helinek G. Scanning electron microscopy of small intestinal repair following treatment for gluten sensitive enteropathy. Scanning Electron Microscopy. 1980;(3):155-161. Not sensitivity or specificity of an identified test. [pmid: 7414261].
Halttunen T, Maki M. Serum immunoglobulin A from patients with celiac disease inhibits human T84 intestinal crypt epithelial cell differentiation. Gastroenterology. 1999;116(3):566-572. Not sensitivity or specificity of an identified test. [pmid: 10029615].
Hamilton I, Cobden I, Rothwell J, et al. Intestinal permeability in coeliac disease: the response to gluten withdrawal and single-dose gluten challenge. Gut. 1982;23(3):202-210. Not sensitivity or specificity of an identified test. [pmid: 6802711]. [pmcid: 1419633].
Hamilton I, Fairris G M, Rothwell J, et al. Small intestinal permeability in dermatological disease. Quarterly Journal of Medicine. 1985;56(221):559-567. Not sensitivity or specificity of an identified test. [pmid: 3933045].
Hamilton I, Hill A, Bose B, et al. Small intestinal permeability in pediatric clinical practice. Journal of Pediatric Gastroenterology and Nutrition. 1987;6(5):697-701. Not sensitivity or specificity of an identified test. [pmid: 3121835].
Hamilton J D, Chambers R A, Wynn Williams A. Role of gluten, prednisone, and azathioprine in non responsive coeliac disease. Lancet. 1976;1(7971):1213-1216. Not sensitivity or specificity of an identified test. [pmid: 58260].
Hamilton J R, McNeill L K. Childhood celiac disease: response of treated patients to a small uniform daily dose of wheat gluten. Journal of Pediatrics. 1972;81(5):885-893. Not sensitivity or specificity of an identified test. [pmid: 5086716].
Hamilton J R, Lynch M J, Reilly B J. Active coeliac disease in childhood. Clinical and laboratory findings of forty-two cases. Quarterly Journal of Medicine 1969;38(150):135-158. Not sensitivity or specificity of an identified test.
Hand D, Campoy F J, Clark S, et al. Activity and distribution of tissue transglutaminase in association with nerve-muscle synapses. J Neurochem. 1993;61(3):1064-1072. Not sensitivity or specificity of an identified test. [pmid: 8103079].
Hansen D, Bennedbaek F N, Hansen L K, et al. High prevalence of coeliac disease in Danish children with type I diabetes mellitus. Acta Paediatrica (Oslo, Norway - 1992). 2001;90(11):1238-1243. Not sensitivity or specificity of an identified test. [pmid: 11808892].
Hansen T, Lundin K E A, Markussen G, et al. T cell receptor usage by HLA-DQ8 specific T cell clones. Eos Riv Immunol Immunofarmacol. 1993;13(1):70-71. Not sensitivity or specificity of an identified test.
Hansson T, Anneren G, Sjoberg O, et al. Celiac disease in relation to immunologic serum markers, trace elements, and HLA-DR and DQ antigens in Swedish children with Down syndrome. Journal of Pediatric Gastroenterology and Nutrition. 1999;29(3):286-292. Improper control group. [pmid: 10467993].
Hansson T, Dannaeus A, Klareskog L. Cytokine-producing cells in peripheral blood of children with coeliac disease secrete cytokines with a type 1 profile. Clinical and Experimental Immunology. 1999;116(2):246-250. Not sensitivity or specificity of an identified test. [pmid: 10337014]. [pmcid: 1905277].
Hansson T, Dannaeus A, Kraaz W, et al. Production of antibodies to gliadin by peripheral blood lymphocytes in children with celiac disease: the use of an enzyme-linked immunospot technique for screening and follow-up. Pediatric Research. 1997;41(4 Pt 1):554-559. Improper control group. [pmid: 9098859].
Hansson T, Ulfgren A-K, Lindroos E, et al. Transforming growth factor-beta (TGF-beta) and tissue transglutaminase expression in the small intestine in children with coeliac disease. Scandinavian Journal of Immunology. 2002;56(5):530-537. Not sensitivity or specificity of an identified test. [pmid: 12410804].
Hansson Tony, Dahlbom Ingrid, Rogberg Siv, et al. Recombinant human tissue transglutaminase for diagnosis and follow-up of childhood coeliac disease. Pediatric Research. 2002;51(6):700-705. Improper control group. [pmid: 12032264].
Hanukoglu A, Mizrachi A, Dalal I, et al. Extrapancreatic autoimmune manifestations in type 1 diabetes patients and their first-degree relatives: A multicenter study. Diabetes Care. 2003;26(4):1235-1240. Not sensitivity or specificity of an identified test. [pmid: 12663603].
Harbeck N, Untch M, Pache L, et al. Tumour cell detection in the bone marrow of breast cancer patients at primary therapy: results of a 3-year median follow-up. British Journal of Cancer. 1994;69(3):566-571. Not sensitivity or specificity of an identified test. [pmid: 7510120].
Hardman C M, Garioch J J, Leonard J N, et al. Absence of toxicity of oats in patients with dermatitis herpetiformis. New England Journal of Medicine. 1997;337(26):1884-1887. Not sensitivity or specificity of an identified test. [pmid: 9407155].
Hardoff D, Levanon D, Gitay H, et al. Evaluation of microville in gluten-sensitive enteropathy by means of scanning and transmission electron microscopy. Journal of Pediatric Gastroenterology and Nutrition. 1986;5(4):560-564. Not sensitivity or specificity of an identified test. [pmid: 3735006].
Harewood G C, Murray J A. Diagnostic approach to a patient with suspected celiac disease: a cost analysis. Digestive Diseases and Sciences. 2001;46(11):2510-2514. Not sensitivity or specificity of an identified test. [pmid: 11713962].
Harley J B, Reichlin M, Arnett F C. Gene interaction at HLA-DQ enhances autoantibody production in primary Sjogren's syndrome. Science. 1986;232(4754):1145-1147. Not sensitivity or specificity of an identified test. [pmid: 3458307].
Harley J B, Sestak A L, Willis L G, et al. A model for disease heterogeneity in systemic lupus erythematosus. Relationships between histocompatibility antigens, autoantibodies, and lymphopenia or renal disease. Arthritis Rheum. 1989;32(7):826-836. Not sensitivity or specificity of an identified test. [pmid: 2787639].
Haroon Z A, Lai T-S, Hettasch J M, et al. Tissue transglutaminase is expressed as a host response to tumor invasion and inhibits tumor growth. Lab Invest. 1999;79(12):1679-1686. Not sensitivity or specificity of an identified test. [pmid: 10616216].
Haroon Z A, Wannenburg T, Gupta M et al. Localization of tissue transglutaminase in human carotid and coronary artery atherosclerosis: implications for plaque stability and progression. Laboratory Investigation 2001;A Journal of Technical Methods and Pathology; 81(1):83–93. Not sensitivity or specificity of an identified test
Harper G D, Wheeler D C, Wicks A C B. Butterfat absorption - a valuable screening test in malabsorption. Postgrad Med J. 1994;70(819):23-26. Not sensitivity or specificity of an identified test. [pmid: 8140013].
Harrison L C, Honeyman M C. Cow's milk and type 1 diabetes: the real debate is about mucosal immune function. Diabetes. 1999;48(8):1501-1507. Not sensitivity or specificity of an identified test. [pmid: 10426365].
Haslam N, Probert C S. An audit of the investigation and treatment of folic acid deficiency. Journal of the Royal Society of Medicine. 1998;91(2):72-73. Not sensitivity or specificity of an identified test. [pmid: 9602741]. [pmcid: 1296488].
Haslam N, Lock R J, Unsworth D J. Coeliac disease, anaemia and pregnancy. Clinical Laboratory. 2001;47(910):467-469. Not sensitivity or specificity of an identified test. [pmid: 11596908].
Hathout E H, Hartwick N, Fagoaga O R, et al. Clinical, autoimmune, and HLA characteristics of children diagnosed with type 1 diabetes before 5 years of age. Pediatrics. 2003;111(4):860-863. Not sensitivity or specificity of an identified test. [pmid: 12671124].
Hattevig G, Kjellman B, Fallstrom S P. Congenital permanent diabetes mellitus and celiac disease. Journal of Pediatrics. 1982;101(6):955-957. Not sensitivity or specificity of an identified test. [pmid: 6754901].
Hauert J, Patston P A, Schapira M. C1 inhibitor cross linking by tissue transglutaminase. Journal of Biological Chemistry. 2000;275(19):14558-14562. Not sensitivity or specificity of an identified test. [pmid: 10799541].
Hauri H P, Kedinger M, Haffen K, et al. Re-evaluation of the techique of organ culture for studying gluten toxicity in coeliac disease. Gut. 1978;19(12):1090-1098. Not sensitivity or specificity of an identified test. [pmid: 744495]. [pmcid: 1412331].
Hausch Felix, Shan Lu, Santiago Nilda A, et al. Intestinal digestive resistance of immunodominant gliadin peptides. American Journal of Physiology. Gastrointestinal and Liver Physiology. 2002;283(4):G996-G1003. Not sensitivity or specificity of an identified test. [pmid: 12223360].
Hayat M, Arora D S, Dixon M F, et al. Effects of Helicobacter pylori eradication on the natural history of lymphocytic gastritis. Gut. 1999;45(4):495-498. Not sensitivity or specificity of an identified test. [pmid: 10486354]. [pmcid: 1727676].
Hayat M, Arora D S, Wyatt J I, et al. The pattern of involvement of the gastric mucosa in lymphocytic gastritis is predictive of the presence of duodenal pathology. Journal of Clinical Pathology. 1999;52(11):815-819. Not sensitivity or specificity of an identified test. [pmid: 10690170]. [pmcid: 501592].
Hayat M, Cairns A, Dixon M F, et al. Quantitation of intraepithelial lymphocytes in human duodenum: what is normal?. Journal of Clinical Pathology. 2002;55(5):393-394. Not sensitivity or specificity of an identified test. [pmid: 11986350]. [pmcid: 1769642].
Haycock G B. Screening test for coeliac disease. Archives of Disease in Childhood. 1976;51(5):401. Not sensitivity or specificity of an identified test. [pmid: 938087].
Hazama H, Omagari K, Masuda J, et al. Serial changes in enzyme inhibitory antibody to pyruvate dehydrogenase complex during the course of primary biliary cirrhosis. Journal of Clinical Laboratory Analysis. 2000;14(5):208-213. Not sensitivity or specificity of an identified test. [pmid: 11018798].
Hazama Hiroaki, Omagari Katsuhisa, Masuda Jun, et al. Automated enzymatic mitochondrial antibody assay for the diagnosis of primary biliary cirrhosis: applications of a routine diagnostic tool for the detection of antimitochondrial antibodies. Journal of Gastroenterology and Hepatology. 2002;17(3):316-323. Not sensitivity or specificity of an identified test. [pmid: 11982703].
Heath D J, Downes S, Verderio E, et al. Characterization of tissue transglutaminase in human osteoblast-like cells. Journal of Bone and Mineral Research - the Official Journal of the American Society for Bone and Mineral Research. 2001;16(8):1477-1485. Not sensitivity or specificity of an identified test. [pmid: 11499870].
Heath Deborah J, Christian Paul, Griffin Martin. Involvement of tissue transglutaminase in the stabilisation of biomaterial/tissue interfaces important in medical devices. Biomaterials. 2002;23(6):1519-1526. Not sensitivity or specificity of an identified test. [pmid: 11829448].
Hed J, Lieden G, Ottosson E. IgA anti-gliadin antibodies and jejunal mucosal lesions in healthy blood donors. Lancet. 1986;2(8500):215. Not sensitivity or specificity of an identified test. [pmid: 2873454].
Hedin C A, Gerner L, Larsson A. The retrocuspid papilla and factor XIIIa: an epidemiologic and histomorphologic study. Scandinavian Journal of Dental Research. 1994;102(5):290-294. Not sensitivity or specificity of an identified test. [pmid: 7529425].
Heine R G, Catto-Smith A G. Antibodies in the diagnosis and management of coeliac disease. J Paediatr Child Health. 1993;29(5):331-334. Not sensitivity or specificity of an identified test. [pmid: 8240859].
Hekimgil M, Soydan S, Nart D, et al. Histopathologic and immunophenotypic features of childhood and adult anaplastic large-cell lymphomas. Turk J Haematol. 2001;18(4):265-274. Not sensitivity or specificity of an identified test.
Hellesen C, Friis T, Larsen E, et al. Small intestinal histology, radiology and absorption in hyperthyroidism. Scandinavian Journal of Gastroenterology. 1969;4(2):169-175. Not sensitivity or specificity of an identified test. [pmid: 4186787].
Helm K F, Peters M S. Immunodermatology update: the immunologically mediated vesiculobullous diseases. Mayo Clinic Proceedings. 1991;66(2):187-202. Not sensitivity or specificity of an identified test. [pmid: 1994137].
Hendrick D J, Faux J A, Anand B, et al. Is bird fancier's lung associated with coeliac disease?. Thorax. 1978;33(4):425-428. Not sensitivity or specificity of an identified test. [pmid: 694796].
Hendrix T R. Interpretation of intestinal biopsies. Gastroenterology. 1968;54(5):976-978. Not sensitivity or specificity of an identified test. [pmid: 5652531].
Heneghan M A, Kearns M, Goulding J, et al. Secretor status and human leucocyte antigens in coeliac disease. Scandinavian Journal of Gastroenterology. 1996;31(10):973-976. Not sensitivity or specificity of an identified test. [pmid: 8898417].
Heneghan M A, McHugh P, Stevens F M, et al. Addison's disease and selective IgA deficiency in two coeliac patients. Scandinavian Journal of Gastroenterology. 1997;32(5):509-511. Not sensitivity or specificity of an identified test. [pmid: 9175216].
Heneghan M A, Stevens F M, Cryan E M, et al. Celiac sprue and immunodeficiency states: a 25-year review. Journal of Clinical Gastroenterology. 1997;25(2):421-425. Not sensitivity or specificity of an identified test. [pmid: 9412941].
Henriksson P, Becker S, Lynch G, et al. Identification of intracellular factor XIII in human monocytes and macrophages. Journal of Clinical Investigation. 1985;76(2):528-534. Not sensitivity or specificity of an identified test. [pmid: 2863285]. [pmcid: 423856].
Herlinger H, Maglinte D D. Jejunal fold separation in adult celiac disease: relevance of enteroclysis. Radiology. 1986;158(3):605-611. Not sensitivity or specificity of an identified test. [pmid: 3945730].
Herman A E, Tisch R M, Patel S D, et al. Determination of glutamic acid decarboxylase 65 peptides presented by the type I diabetes-associated HLA-DQ8 class II molecule identifies an immunogenic peptide motif. J Immunol. 1999;163(11):6275-6282. Not sensitivity or specificity of an identified test. [pmid: 10570321].
Hermann R, Soltesz G. Prevalence and HLA association of GAD65 antibodies in Hungarian schoolchildren. Hum Immunol. 2003;64(1):152-155. Not sensitivity or specificity of an identified test. [pmid: 12507826].
Hermann R, Mijovic C H, Rayner M, et al. HLA alleles and IDDM in children in Hungary: a comparison with Finland. Human Immunology. 2001;62(4):391-398. Not sensitivity or specificity of an identified test. [pmid: 11295472].
Hernandez J L, Michalski J P, McCombs C C, et al. Evidence for a dominant gene mechanism underlying coeliac disease in the west of Ireland. Genetic Epidemiology. 1991;8(1):13-27. Not sensitivity or specificity of an identified test. [pmid: 2060769].
Hernandez M A, Colina G, Ortigosa L. Epilepsy, cerebral calcifications and clinical or subclinical coeliac disease. Course and follow up with gluten-free diet. Seizure - the Journal of the British Epilepsy Association. 1998;7(1):49-54. Not sensitivity or specificity of an identified test. [pmid: 9548226].
Hernandez M, Argente J, Navarro A, et al. Growth in malnutrition related to gastrointestinal diseases: Coeliac disease. Horm Res. 1992;38(Suppl 1):79-84. Not sensitivity or specificity of an identified test. [pmid: 1284243].
Hernanz A, Polanco I, Codoceo R. Gastrointestinal peptide profile in children with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1987;6(3):341-345. Not sensitivity or specificity of an identified test. [pmid: 2892903].
Herrera M, Chertkoff L, Palavecino E, et al. Restriction fragment length polymorphism in HLA class II genes of Latin-American Caucasian celiac disease patients. Human Immunology. 1989;26(4):272-280. Not sensitivity or specificity of an identified test. [pmid: 2573590].
Herrera M, Theiler G, Augustovski F, et al. Molecular characterization of HLA class II genes in celiac disease patients of Latin American Caucasian origin. Tissue Antigens. 1994;43(2):83-87. Improper control group. [pmid: 8016846].
Herron M D, Zone J J. Treatment of dermatitis herpetiformis and linear IgA bullous dermatosis. Dermatol Ther. 2002;15(4):374-381. Not sensitivity or specificity of an identified test.
Hertervig E, Wieslander J, Johansson C, et al. Anti-neutrophil cytoplasmic antibodies in chronic inflammatory bowel disease. Prevalence and diagnostic role. Scandinavian Journal of Gastroenterology. 1995;30(7):693-698. Not sensitivity or specificity of an identified test. [pmid: 7481534].
Herulf M, Blomquist L, Ljung T, et al. Increased rectal nitric oxide in coeliac disease after local challenge with gluten. Scandinavian Journal of Gastroenterology. 2001;36(2):169-173. Not sensitivity or specificity of an identified test. [pmid: 11252409].
Hervonen K, Karell K, Holopainen P, et al. Concordance of dermatitis herpetiformis and celiac disease in monozygous twins. Journal of Investigative Dermatology. 2000;115(6):990-993. Not sensitivity or specificity of an identified test. [pmid: 11121131].
Hessels J, Eidhof H H M, Steggink J, et al. Assessment of hypolactasia and site-specific intestinal permeability of differential sugar absorption of raffinose, lactose, sucrose and mannitol. Clin Chem Lab Med. 2003;41(8):1056-1063. Not sensitivity or specificity of an identified test. [pmid: 12964814].
Hettasch J M, Bandarenko N, Burchette J L, et al. Tissue transglutaminase expression in human breast cancer. Laboratory Investigation. 1996;75(5):637-645. Not sensitivity or specificity of an identified test. [pmid: 8941210].
Hettasch J M, Peoples K A, Greenberg C S. Analysis of factor XIII substrate specificity using recombinant human factor XIII and tissue transglutaminase Chimeras. J Biol Chem. 1997;272(40):25149-25156. Not sensitivity or specificity of an identified test. [pmid: 9312126].
Hetzel P A, Bennett G D, Sheldon A B, et al. Genetic markers in Australian Caucasian subjects with coeliac disease. Tissue Antigens. 1987;30(1):18-22. Not sensitivity or specificity of an identified test. [pmid: 3118502].
Heurkens A H, Hiemstra P S, Lafeber G J, et al. Anti-endothelial cell antibodies in patients with rheumatoid arthritis complicated by vasculitis. Clinical and Experimental Immunology. 1989;78(1):7-12. Not sensitivity or specificity of an identified test. [pmid: 2805426]. [pmcid: 1534594].
Hevessy Z, Patthy A, Karpati L, et al. alpha(2)-plasmin inhibitor is a substrate for tissue transglutaminase: an in vitro study. Thrombosis Research. 2000;99(4):399-406. Not sensitivity or specificity of an identified test. [pmid: 10963790].
Heward J M, Mijovic C H, Kelly M A, et al. HLA-DQ and DRB1 polymorphism and susceptibility to type 1 diabetes in Jamaica. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 2002;29(1):47-52. Not sensitivity or specificity of an identified test. [pmid: 11841488].
Hidasi V, Adany R, Muszbek L. Localization of transglutaminase in human lenses. Journal of Histochemistry and Cytochemistry - Official Journal of the Histochemistry Society. 1995;43(11):1173-1177. Not sensitivity or specificity of an identified test.
Hide D W, Burman D. An infant with both cystic fibrosis and coeliac disease. Archives of Disease in Childhood. 1969;44(236):533-535. Not sensitivity or specificity of an identified test. [pmid: 5803646].
Higounenc I, Demarchez M, Regnier M, et al. Improvement of epidermal differentiation and barrier function in reconstructed human skin after grafting onto athymic nude mice. Archives of Dermatological Research. 1994;286(2):107-114. Not sensitivity or specificity of an identified test. [pmid: 8154923].
Hiiragi T, Sasaki H, Nagafuchi A, et al. Transglutaminase type 1 and its cross-linking activity are concentrated at adherens junctions in simple epithelial cells. Journal of Biological Chemistry. 1999;274(48):34148-34154. Not sensitivity or specificity of an identified test. [pmid: 10567386].
Hill A V S. Immunogenetics and genomics. Lancet. 2001;357(9273):2037-2041. Not sensitivity or specificity of an identified test. [pmid: 11747915].
Hill I D. Celiac disease - A never-ending story?. Journal of Pediatrics. 2003;143(3):289-291. Not sensitivity or specificity of an identified test. [pmid: 14517506].
Hill I, Fasano A, Schwartz R, et al. The prevalence of celiac disease in at-risk groups of children in the United States. Journal of Pediatrics. 2000;136(1):86-90. Not sensitivity or specificity of an identified test. [pmid: 10636980].
Hill P G, Thompson S P, Holmes G K. IgA anti-gliadin antibodies in adult celiac disease. Clinical Chemistry. 1991;37(5):647-650. Improper control group. [pmid: 2032317].
Hill R, Cutz E, Cherian G, et al. An evaluation of D-xylose absorption measurements in children suspected of having small intestinal disease. Journal of Pediatrics. 1981;99(2):245-247. Not sensitivity or specificity of an identified test. [pmid: 7252685].
Hill S M, Phillips A D, Mearns M, et al. Cows' milk sensitive enteropathy in cystic fibrosis. Archives of Disease in Childhood. 1989;64(9):1251-1255. Not sensitivity or specificity of an identified test. [pmid: 2817944].
Hillert J, Kall T, Olerup O, et al. Distribution of HLA-Dw2 in optic neuritis and multiple sclerosis indicates heterogeneity. Acta Neurol Scand. 1996;94(3):161-166. Not sensitivity or specificity of an identified test. [pmid: 8899048].
Hilton D A, Love S, Barber R. Increased endothelial expression of transglutaminase in glioblastomas. Neuropathology and Applied Neurobiology. 1997;23(6):507-511. Not sensitivity or specificity of an identified test. [pmid: 9460717].
Hin H, Bird G, Fisher P, et al. Coeliac disease in primary care: case finding study. Bmj (Clinical Research Ed.). 1999;318(7177):164-167. Not sensitivity or specificity of an identified test. [pmid: 9888912].
Hines M D, Jin H C, Wheelock M J, et al. Inhibition of cadherin function differentially affects markers of terminal differentiation in cultured human keratinocytes. Journal of Cell Science. 1999;112(Pt 24):4569-4579. Not sensitivity or specificity of an identified test. [pmid: 10574706].
Hinks L J, Inwards K D, Lloyd B, et al. Body content of selenium in coeliac disease. Br Med J. 1984;288(6434):1862-1863. Not sensitivity or specificity of an identified test. [pmid: 6428578]. [pmcid: 1441793].
Hirao T, Denda M, Takahashi M. Identification of immature cornified envelopes in the barrier-impaired epidermis by characterization of their hydrophobicity and antigenicities of the components. Experimental Dermatology. 2001;10(1):35-44. Not sensitivity or specificity of an identified test. [pmid: 11168578].
Hitman G A, Niven M J, Festenstein H, et al. HLA class II alpha chain gene polymorphisms in patients with insulin-dependent diabetes mellitus, dermatitis herpetiformis, and celiac disease. Journal of Clinical Investigation. 1987;79(2):609-615. Not sensitivity or specificity of an identified test. [pmid: 3805283]. [pmcid: 424142].
Hitomi K, Presland R B, Nakayama T, et al. Analysis of epidermal-type transglutaminase (transglutaminase 3) in human stratified epithelia and cultured keratinocytes using monoclonal antibodies. J Dermatol Sci. 2003;32(2):95-103. Not sensitivity or specificity of an identified test. [pmid: 12850301].
Hjelmstrom P, Giscombe R, Lefvert A K, et al. TAP polymorphisms in Swedish myasthenia gravis patients. Tissue Antigens. 1997;49(2):176-179. Not sensitivity or specificity of an identified test. [pmid: 9062975].
Ho G J, Gregory E J, Smirnova I V, et al. Cross-linking of beta-amyloid protein precursor catalyzed by tissue transglutaminase. Febs Letters. 1994;349(1):151-154. Not sensitivity or specificity of an identified test. [pmid: 7913896].
Ho K C, Quarmby V E, French F S, et al. Molecular cloning of rat prostate transglutaminase complementary DNA. The major androgen-regulated protein DP1 of rat dorsal prostate and coagulating gland. Journal of Biological Chemistry. 1992;267(18):12660-12667. Not sensitivity or specificity of an identified test. [pmid: 1352290].
Hodges J R, Isaacson P, Smith C L, et al. Malignant histiocytosis of the intestine. Digestive Diseases and Sciences. 1979;24(8):631-638. Not sensitivity or specificity of an identified test. [pmid: 467214].
Hodges S, Lobo-Yeo A, Donaldson P, et al. Autoimmune chronic active hepatitis in a family. Gut. 1991;32(3):299-302. Not sensitivity or specificity of an identified test. [pmid: 2013424]. [pmcid: 1378838].
Hoey J. Irritable bowel syndrome: Could it be celiac disease?. Can Med Assoc J. 2002;166(4):479-480. Not sensitivity or specificity of an identified test. [pmid: 11873929]. [pmcid: 99362].
Hoffbrand A V. Anaemia in adult coeliac disease. Clin Gastroenterol. 1974;3(1):71-89. Not sensitivity or specificity of an identified test. [pmid: 4599262].
Hoffenberg E J, Bao F, Eisenbarth G S, et al. Transglutaminase antibodies in children with a genetic risk for celiac disease. Journal of Pediatrics. 2000;137(3):356-360. Unable to extract data. [pmid: 10969260].
Hoffenberg E J, Haas J, Drescher A, et al. A trial of oats in children with newly diagnosed celiac disease. Journal of Pediatrics. 2000;137(3):361-366. Not sensitivity or specificity of an identified test. [pmid: 10969261].
Hoffenberg E J, Mackenzie T, Barriga K J, et al. A prospective study of the incidence of childhood celiac disease. Journal of Pediatrics. 2003;143(3):308-314. Not sensitivity or specificity of an identified test. [pmid: 14517510].
Hoffmann M, Vogelsang H, Kletter K, et al. 18F-fluoro-deoxy-glucose positron emission tomography (18F-FDG-PET) for assessment of enteropathy-type T cell lymphoma. Gut. 2003;52(3):347-351. Not sensitivity or specificity of an identified test. [pmid: 12584214]. [pmcid: 1773540].
Hogberg L, Falth-Magnusson K, Grodzinsky E, et al. Familial prevalence of coeliac disease: A twenty-year follow-up study. Scandinavian Journal of Gastroenterology. 2003;38(1):61-65. Not sensitivity or specificity of an identified test. [pmid: 12608466].
Hogberg L, Grodzinsky E, Stenhammar L. Better dietary compliance in patients with coeliac disease diagnosed in early childhood. Scandinavian Journal of Gastroenterology. 2003;38(7):751-754. Not sensitivity or specificity of an identified test. [pmid: 12889562].
Hogberg L, Nordwall M, Stenhammar L. One thousand small-bowel biopsies in children. A single-port versus a double-port capsule. Scandinavian Journal of Gastroenterology. 2001;36(11):1230-1232. Not sensitivity or specificity of an identified test. [pmid: 11686227].
Hogberg L, Nordwall M, Stenhammar L. Small bowel capsule biopsy in children: parents' opinions on children's discomfort. Acta Paediatrica (Oslo, Norway - 1992). 2001;90(8):876-878. Not sensitivity or specificity of an identified test. [pmid: 11529534].
Hohenadl C, Mann K, Mayer U, et al. Two adjacent N-terminal glutamines of BM-40 (osteonectin, SPARC) act as amine acceptor sites in transglutaminaseC-catalyzed modification. Journal of Biological Chemistry. 1995;270(40):23415-23420. Not sensitivity or specificity of an identified test. [pmid: 7559501].
Hohl D. Expression patterns of loricrin in dermatological disorders. American Journal of Dermatopathology. 1993;15(1):20-27. Not sensitivity or specificity of an identified test. [pmid: 8434728].
Hohl D, Aeschlimann D, Huber M. In vitro and rapid in situ transglutaminase assays for congenital ichthyoses--a comparative study. Journal of Investigative Dermatology. 1998;110(3):268-271. Not sensitivity or specificity of an identified test. [pmid: 9506447].
Hohl D, de Viragh P A, Amiguet-Barras F, et al. The small proline-rich proteins constitute a multigene family of differentially regulated cornified cell envelope precursor proteins. Journal of Investigative Dermatology. 1995;104(6):902-909. Not sensitivity or specificity of an identified test. [pmid: 7769256].
Hohl D, Huber M, Frenk E. Analysis of the cornified cell envelope in lamellar ichthyosis. Archives of Dermatology. 1993;129(5):618-624. Not sensitivity or specificity of an identified test. [pmid: 8097623].
Holdstock D J, Oleesky S. Successful treatment of collagenous sprue with combination of prednisolone and gluten free diet. Postgrad Med J. 1973;49(575):664-667. Not sensitivity or specificity of an identified test. [pmid: 4788921].
Holdstock G. Jejunal biopsy without the need for screening. Lancet. 1978;1(8076):1236-1237. Not sensitivity or specificity of an identified test. [pmid: 77999].
Holdstock G, Eade O E, Isaacson P, et al. Endoscopic duodenal biopsies in coeliac disease and duodenitis. Scandinavian Journal of Gastroenterology. 1979;14(6):717-720. Unable to extract data. [pmid: 531504].
Holl R W, Grabert M, Heinze E, et al. Age at onset and long-term metabolic control affect height in type-1 diabetes mellitus. European Journal of Pediatrics. 1998;157(12):972-977. Not sensitivity or specificity of an identified test. [pmid: 9877034].
Hollen E, Hogberg L, Stenhammar L, et al. Antibodies to oat prolamines (avenins) in children with coeliac disease. Scandinavian Journal of Gastroenterology. 2003;38(7):742-746. Not sensitivity or specificity of an identified test. [pmid: 12889560].
Holm K, Maki M, Savilahti E, et al. Intraepithelial gamma delta T-cell-receptor lymphocytes and genetic susceptibility to coeliac disease. Lancet. 1992;339(8808):1500-1503. Not sensitivity or specificity of an identified test. [pmid: 1351185].
Holm K, Savilahti E, Koskimies S, et al. Immunohistochemical changes in the jejunum in first degree relatives of patients with coeliac disease and the coeliac disease marker DQ genes. HLA class II antigen expression, interleukin-2 receptor positive cells and dividing crypt cells. Gut. 1994;35(1):55-60. Unable to extract data. [pmid: 8307450]. [pmcid: 1374632].
Holmes G K. Coeliac disease and Type 1 diabetes mellitus - the case for screening. Diabetic Medicine - a Journal of the British Diabetic Association. 2001;18(3):169-177. Not sensitivity or specificity of an identified test. [pmid: 11318836].
Holmes G K T. Screening for coeliac disease in type 1 diabetes. Archives of Disease in Childhood. 2002;87(6):495-498. Not sensitivity or specificity of an identified test. [pmid: 12456547].
Holmes G K T, Stokes P L, Sorahan T M. Coeliac disease, gluten free diet, and malignancy. Gut. 1976;17(8):612-619. Not sensitivity or specificity of an identified test. [pmid: 789184]. [pmcid: 1411326].
Holmes G K, Asquith P, Stokes P L, et al. Cellular infiltrate of jejunal biopsies in adult coeliac disease (ACD) in relation to gluten withdrawal. Gut. 1973;14(5):429. Not sensitivity or specificity of an identified test. [pmid: 4743492].
Holmes G K, Asquith P, Stokes P L, et al. Cellular infiltrate of jejunal biopsies in adult coeliac disease in relation to gluten withdrawal. Gut. 1974;15(4):278-283. Not sensitivity or specificity of an identified test. [pmid: 4834552]. [pmcid: 1412953].
Holmgren Peterson K, Falth-Magnusson K, Magnusson K E, et al. Children with celiac disease express inducible nitric oxide synthase in the small intestine during gluten challenge. Scandinavian Journal of Gastroenterology. 1998;33(9):939-943. Not sensitivity or specificity of an identified test. [pmid: 9759949].
Holmgren Peterson K, Magnusson K E, Stenhammar L, et al. Confocal laser scanning microscopy of small-intestinal mucosa in celiac disease. Scandinavian Journal of Gastroenterology. 1995;30(3):228-234. Not sensitivity or specificity of an identified test. [pmid: 7539542].
Holopainen P, Arvas M, Sistonen P, et al. CD28/CTLA4 gene region on chromosome 2q33 confers genetic susceptibility to celiac disease. A linkage and family-based association study. Tissue Antigens. 1999;53(5):470-475. Not sensitivity or specificity of an identified test. [pmid: 10372542].
Holopainen P, Mustalahti K, Uimari P, et al. Candidate gene regions and genetic heterogeneity in gluten sensitivity. Gut. 2001;48(5):696-701. Improper control group. [pmid: 11302971]. [pmcid: 1728294].
Honeyman M C, Harrison L C, Drummond B, et al. Analysis of families at risk for insulin-dependent diabetes mellitus reveals that HLA antigens influence progression to clinical disease. Molecular Medicine (Cambridge, Mass.). 1995;1(5):576-582. Not sensitivity or specificity of an identified test. [pmid: 8529124].
Horejsi V, Nemec M, Angelisova P. Characterization of seven new monoclonal antibodies against human DR, DR + DP and DQ1 +DQ3 antigens. Tissue Antigens. 1986;28(5):288-297. Not sensitivity or specificity of an identified test. [pmid: 2435017].
Horikoshi T, Arany I, Rajaraman S, et al. Isoforms of cathepsin D and human epidermal differentiation. Biochimie. 1998;80(7):605-612. Not sensitivity or specificity of an identified test. [pmid: 9810467].
Horvath K, Mehta D I. Celiac disease--a worldwide problem. Indian Journal of Pediatrics. 2000;67(10):757-763. Not sensitivity or specificity of an identified test. [pmid: 11105427].
Horvath K, Horn G, Bodanszky H, et al. Disaccharidases in coeliac disease. Acta Paediatrica Hungarica. 1983;24(2):131-136. Not sensitivity or specificity of an identified test. [pmid: 6613572].
Horvath K, Nagy L, Horn G, et al. Intestinal mast cell and neutrophil chemotactic activity of serum following a single challenge with gluten in celiac children on a gluten-free diet. Journal of Pediatric Gastroenterology and Nutrition. 1989;9(3):276-280. Not sensitivity or specificity of an identified test. [pmid: 2614612].
Horvath Karoly, Hill Ivor D. Anti-tissue transglutaminase antibody as the first line screening for celiac disease: good-bye antigliadin tests?. American Journal of Gastroenterology. 2002;97(11):2702-2704. Review article. [pmid: 12425536].
Hosokawa K, Hosokawa H, Futamura S, et al. Proteins of the cornified envelope. Journal of Dermatology. 1992;19(11):744-748. Not sensitivity or specificity of an identified test. [pmid: 1284066].
Houlston R S, Ford D. Genetics of coeliac disease. Qjm-Monthly Journal of the Association of Physicians. 1996;89(10):737-743. Not sensitivity or specificity of an identified test. [pmid: 8944229].
Houlston R S, Tomlinson I P, Ford D, et al. Linkage analysis of candidate regions for coeliac disease genes. Human Molecular Genetics. 1997;6(8):1335-1339. Not sensitivity or specificity of an identified test. [pmid: 9259281].
Housseau F, Rouas-Freiss N, Benifla J-L, et al. Reaction of peripheral-blood lymphocytes to the human chorionic gonadotropin beta sub-unit in patients with productive tumors. Int J Cancer. 1995;63(5):633-638. Not sensitivity or specificity of an identified test. [pmid: 7591278].
Hovdenak N. Prevalence and clinical picture of adult gluten-induced enteropathy in a Norwegian population. Scandinavian Journal of Gastroenterology. 1980;15(4):401-404. Not sensitivity or specificity of an identified test. [pmid: 7433901].
Hovdenak N, Hovlid E, Aksnes L, et al. High prevalence of asymptomatic coeliac disease in Norway: a study of blood donors. European Journal of Gastroenterology & Hepatology. 1999;11(2):185-187. Not sensitivity or specificity of an identified test. [pmid: 10102231].
Hovell C J, Collett J A, Vautier G, et al. High prevalence of coeliac disease in a population-based study from Western Australia: a case for screening?. Medical Journal of Australia. 2001;175(5):247-250. Not sensitivity or specificity of an identified test. [pmid: 11587254].
Howard M R, Turnbull A J, Morley P, et al. A prospective study of the prevalence of undiagnosed coeliac disease in laboratory defined iron and folate deficiency. J Clin Pathol. 2002;55(10):754-757. Not sensitivity or specificity of an identified test. [pmid: 12354801]. [pmcid: 1769776].
Howat A J, Mcphie J L, Smith D A, et al. Cavitation of mesenteric lymph nodes: A rare complication of coeliac disease, associated with a poor outcome. Histopathology. 1995;27(4):349-354. Not sensitivity or specificity of an identified test. [pmid: 8847065].
Howdle P D, Blair G E. Molecular biology and coeliac disease. Gut. 1992;33(5):573-575. Not sensitivity or specificity of an identified test. [pmid: 1612470]. [pmcid: 1379279].
Howdle P D, Bullen A W, Losowsky M S. Cell-mediated immunity to gluten within the small intestinal mucosa in coeliac disease. Gut. 1982;23(2):115-122. Not sensitivity or specificity of an identified test. [pmid: 7040172]. [pmcid: 1419547].
Howdle P D, Corazza G R, Bullen A W, et al. In vitro diagnosis of coeliac disease: an assessment. Gut. 1981;22(11):939-947. Not sensitivity or specificity of an identified test. [pmid: 7030878]. [pmcid: 1419470].
Howell M D, Austin R K, Kelleher D, et al. An HLA-D region restriction fragment length polymorphism associated with celiac disease. Journal of Experimental Medicine. 1986;164(1):333-338. Not sensitivity or specificity of an identified test. [pmid: 3014038].
Howell M D, Smith J R, Austin R K, et al. An extended HLA-D region haplotype associated with celiac disease. Proc Natl Acad Sci U S A. 1988;85(1):222-226. Not sensitivity or specificity of an identified test. [pmid: 2893373]. [pmcid: 279516].
Howell W M, Jones D B. The role of human leucocyte antigen genes in the development of malignant disease. J Clin Pathol Clin Mol Pathol. 1995;48(6):M302-M306. Not sensitivity or specificity of an identified test.
Howell W M, Calder P C, Grimble R F. Symposium on ‘nutrition in the post-genomic era’. Plenary session 4: Genetic variation and diet-related disease: Gene polymorphisms, inflammatory diseases and cancer. Proc Nutr Soc. 2002;61(4):447-456. Not sensitivity or specificity of an identified test. [pmid: 12691174].
Howell W M, Leung S T, Jones D B, et al. HLA-DRB, -DQA, and -DQB polymorphism in celiac disease and enteropathy-associated T-cell lymphoma. Common features and additional risk factors for malignancy. Human Immunology. 1995;43(1):29-37. Improper control group. [pmid: 7558926].
Howell W, Martin Calder, Philip C, et al. Gene polymorphisms, inflammatory diseases and cancer. Proceedings of the Nutrition Society. 2002;61(4):447-456. Not sensitivity or specificity of an identified test. [pmid: 12691174].
Hozyasz K K. Sex ratio variation in offspring of celiac women - Preliminary report. Pediatr Wspolczesna. 2002;4(3):253-255. Not sensitivity or specificity of an identified test.
Hudson D A, Anderson C M. A new experimental system for the study of the pathogenesis of coeliac disease. Lancet. 1977;1(8010):511-512. Not sensitivity or specificity of an identified test. [pmid: 65611].
Huff Thomas, Otto Angela M, Muller Christian S G, et al. Thymosin beta4 is released from human blood platelets and attached by factor XIIIa (transglutaminase) to fibrin and collagen. Faseb Journal - Official Publication of the Federation of American Societies for Experimental Biology. 2002;16(7):691-696. Not sensitivity or specificity of an identified test.
Hummel M, Bonifacio E, Stern M, et al. Development of celiac disease-associated antibodies in offspring of parents with type I diabetes. Diabetologia. 2000;43(8):1005-1011. Not sensitivity or specificity of an identified test. [pmid: 10990078].
Hummel M, Ziegler A G, Bonifacio E. Type 1 diabetes mellitus, celiac disease and their association - Lessons from antibodies. J Pediatr Endocrinol Metab. 2001;14(Suppl 1):607-610. Not sensitivity or specificity of an identified test. [pmid: 11393551].
Hummel Michael, Bonifacio Ezio, Naserke Heike E, et al. Elimination of dietary gluten does not reduce titers of type 1 diabetes-associated autoantibodies in high-risk subjects. Diabetes Care. 2002;25(7):1111-1116. Not sensitivity or specificity of an identified test. [pmid: 12087006].
Hunter I P, Ferguson M M, Scully C, et al. Effects of dietary gluten elimination in patients with recurrent minor aphthous stomatitis and no detectable gluten enteropathy. Oral Surg Oral Med Oral Pathol. 1993;75(5):595-598. Not sensitivity or specificity of an identified test. [pmid: 8488028].
Huq M I. A simple laboratory method for the diagnosis of V. cholerae. Transactions of the Royal Society of Tropical Medicine and Hygiene. 1979;73(5):553-556. Not sensitivity or specificity of an identified test. [pmid: 394411].
Huq M I, Sanyal S C, Samadi A R, et al. Comparative behaviour of classical and El Tor biotypes of Vibrio cholerae 01 isolated in Bangladesh during 1982. Journal of Diarrhoeal Diseases Research. 1983;1(1):5-9. Not sensitivity or specificity of an identified test. [pmid: 6384354].
Husby S. Normal immune responses to ingested foods. Journal of Pediatric Gastroenterology and Nutrition. 2000;30(Suppl):s13-s19. Not sensitivity or specificity of an identified test. [pmid: 10634294].
Hussain G, Ali S, Iqbal M M, et al. Study of coeliac disease in children. J Coll Phys Surg Pak. 1999;9(2):81-84. Not sensitivity or specificity of an identified test.
Hwang K C, Gray C D, Sivasubramanian N, et al. Interaction site of GTP binding Gh (transglutaminase II) with phospholipase C. Journal of Biological Chemistry. 1995;270(45):27058-27062. Not sensitivity or specificity of an identified test. [pmid: 7592956].
Hyams J S, Treem W R, Justinich C J, et al. Characterization of symptoms in children with recurrent abdominal pain: resemblance to irritable bowel syndrome. Journal of Pediatric Gastroenterology and Nutrition. 1995;20(2):209-214. Not sensitivity or specificity of an identified test. [pmid: 8583293].
Iacono G, Carroccio A, Montalto G, et al. Steatocrit test after a standard fatty meal: a new simple and sensitive test to detect malabsorption. Journal of Pediatric Gastroenterology and Nutrition. 1991;13(2):161-167. Not sensitivity or specificity of an identified test. [pmid: 1941409].
Iancu T, Elian E. The intestinal microvillus. Ultrastructural variability in coeliac disease and cow's milk intolerance. Acta Paediatrica Scandinavica. 1976;65(1):65-73. Not sensitivity or specificity of an identified test. [pmid: 1251726].
Ichikawa S, Hatanaka H, Yuuki T, et al. Solution structure of Der f 2, the major mite allergen for atopic diseases. Journal of Biological Chemistry. 1998;273(1):356-360. Not sensitivity or specificity of an identified test. [pmid: 9417088].
Ichinose A, Hendrickson L E, Fujikawa K, et al. Amino acid sequence of the a subunit of human factor XIII. Biochemistry. 1986;25(22):6900-6906. Not sensitivity or specificity of an identified test. [pmid: 3026437].
Ide A, Eisenbarth G S. Genetic susceptibility in type 1 diabetes and its associated autoimmune disorders. Rev Endocr Metab Disord. 2003;4(3):243-253. Not sensitivity or specificity of an identified test. [pmid: 14501175].
Ientile R, Merendino R A, Fabiano C, et al. Polyamines are involved in retinoic acid-mediated induction of tissue transglutaminase in human peripheral blood monocytes. Research Communications in Chemical Pathology and Pharmacology. 1992;77(3):313-326. Not sensitivity or specificity of an identified test. [pmid: 1360694].
Iijima Junko, Shiina Yoshio, Ohkoudo Mitsuaki, et al. Usefulness of Auto Cyto Fix (membrane filter method) for the application of immunohistochemistry. Diagnostic Cytopathology. 2002;26(1):56-60. Not sensitivity or specificity of an identified test. [pmid: 11782090].
Iismaa S E. Structure and function of tissue transglutaminase. Minerva Biotecnol. 2002;14(2):113-119. Not sensitivity or specificity of an identified test.
Ikaheimo I, Silvennoinen-Kassinen S, Tiilikainen A. HLA five-locus haplotypes in Finns. Eur J Immunogenet. 1996;23(4):321-328. Not sensitivity or specificity of an identified test. [pmid: 8858288].
Ikaheimo I, Silvennoinen-Kassinen S, Karvonen J, et al. Immunogenetic profile of psoriasis vulgaris: Association with haplotypes A2,B13,Cw6,DR7,DQA1*0201 and A1,B17,Cw6,DR7,DQA1*0201. Arch Dermatol Res. 1996;288(2):63-67. Not sensitivity or specificity of an identified test. [pmid: 8818183].
Illingworth A L, Young J A, Johnson G D. Immunofluorescent staining of metastatic carcinoma cells in serious fluid with carcinoembryonic antibody, epithelial membrane antibody, AUA-1 and Ber-EP4. Cytopathology - Official Journal of the British Society for Clinical Cytology. 1994;5(5):270-281. Not sensitivity or specificity of an identified test. [pmid: 7819512].
Illueca C, Llombart-Bosch A, Ferrando Cucarella J. Prognostic factors in Barrett's esophagus: an immunohistochemical and morphometric study of 120 cases. Revista Espanola De Enfermedades Digestivas - Organo Oficial De La Sociedad Espanola De Patologia Digestiva. 2000;92(11):726-737. Not sensitivity or specificity of an identified test. [pmid: 11468854].
Ilonen J, Merivuori H, Reijonen H, et al. Tumour necrosis factor-beta gene RFLP alleles in Finnish IDDM haplotypes. Scand J Immunol. 1992;36(6):779-783. Not sensitivity or specificity of an identified test. [pmid: 1361076].
Iltanen S, Collin P, Korpela M, et al. Celiac disease and markers of celiac disease latency in patients with primary Sjogren's syndrome. American Journal of Gastroenterology. 1999;94(4):1042-1046. Improper control group. [pmid: 10201480].
Iltanen S, Holm K, Ashorn M, et al. Changing jejunal gamma delta T cell receptor (TCR)-bearing intraepithelial lymphocyte density in coeliac disease. Clinical and Experimental Immunology. 1999;117(1):51-55. Not sensitivity or specificity of an identified test. [pmid: 10403915]. [pmcid: 1905475].
Iltanen S, Rantala I, Laippala P, et al. Expression of HSP-65 in jejunal epithelial cells in patients clinically suspected of coeliac disease. Autoimmunity. 1999;31(2):125-132. Improper control group. [pmid: 10680751].
Indovina P, Megiorni F, Fontemaggi G, et al. Absence of in vivo DNA-protein interactions in the DQA2 and DQB2 promoter regions. Hum Immunol. 2001;62(5):504-508. Not sensitivity or specificity of an identified test. [pmid: 11334674].
Isaacson P, Wright D H. Intestinal lymphoma associated with malabsorption. Lancet. 1978;1(8055):67-70. Not sensitivity or specificity of an identified test. [pmid: 76907].
Isaacson P G. Relation between cryptic intestinal lymphoma and refractory sprue. Lancet. 2000;356(9225):178-179. Not sensitivity or specificity of an identified test. [pmid: 10963189].
Isaacson P G. T-cell lymphoma: The real thing. Gut. 1999;45(5):638-639. Not sensitivity or specificity of an identified test. [pmid: 10517893]. [pmcid: 1727717].
Isbell R G, Carlson H C, Hoffman H N. Roentgenologic-pathologic correlation in malabsorption syndromes. American Journal of Roentgenology, Radium Therapy, and Nuclear Medicine. 1969;107(1):158-169. Not sensitivity or specificity of an identified test.
Ishido T, Mori N. Primary gastric plasmacytoma: a morphological and immunohistochemical study of five cases. American Journal of Gastroenterology. 1992;87(7):875-878. Not sensitivity or specificity of an identified test. [pmid: 1615942].
Ivarsson A, Persson L A, Juto P, et al. High prevalence of undiagnosed coeliac disease in adults: a Swedish population-based study. Journal of Internal Medicine. 1999;245(1):63-68. Not sensitivity or specificity of an identified test. [pmid: 10095818].
Ivarsson S A, Carlsson A, Bredberg A, et al. Prevalence of coeliac disease in Turner syndrome. Acta Paediatrica (Oslo, Norway - 1992). 1999;88(9):933-936. Not sensitivity or specificity of an identified test. [pmid: 10519331].
Iwaki T, Miyazono M, Hitosumatsu T, et al. An immunohistochemical study of tissue transglutaminase in gliomas with reference to their cell dying processes. American Journal of Pathology. 1994;145(4):776-781. Not sensitivity or specificity of an identified test. [pmid: 7524329]. [pmcid: 1887323].
Iwanczak F, Iwanczak B, Matusiewicz K, et al. Assessment of serum antibodies against gliadin, endomysium and tissue transglutaminase in diagnosis of celiac disease in children. Gastroenterol Pol. 2003;10(4):323-328. Unable to obtain full article.
Jabbar A A. HLA and disease associations in Iraq. Disease Markers. 1993;11(4):161-170. Not sensitivity or specificity of an identified test. [pmid: 8112020].
Jabbari M, Wild G, Goresky C A, et al. Scalloped valvulae conniventes: an endoscopic marker of celiac sprue. Gastroenterology. 1988;95(6):1518-1522. Not sensitivity or specificity of an identified test. [pmid: 3181676].
Jabri B, de Serre N P, Cellier C, et al. Selective expansion of intraepithelial lymphocytes expressing the HLA-E-specific natural killer receptor CD94 in celiac disease. Gastroenterology. 2000;118(5):867-879. Not sensitivity or specificity of an identified test. [pmid: 10784586].
Jackson D, Walker-Smith J A, Phillips A D. Passive diffusion in small intestinal mucosa in childhood. Histopathology. 1982;6(6):689-702. Not sensitivity or specificity of an identified test. [pmid: 6186593].
Jaeger C, Hatziagelaki E, Petzoldt R, et al. Comparative analysis of organ-specific autoantibodies and celiac disease--associated antibodies in type 1 diabetic patients, their first-degree relatives, and healthy control subjects. Diabetes Care. 2001;24(1):27-32. Not sensitivity or specificity of an identified test. [pmid: 11194235].
Jafarzadeh A, Shokrgozar M A, Khoshnoodi J, et al. Unresponsiveness to recombinant hepatitis B vaccine in healthy Iranian neonates: Association with HLA antigens. Iran J Med Sci. 2002;27(2):51-55. Not sensitivity or specificity of an identified test.
Jagerstad M, Lindstrand K, Norden A, et al. The folate conjugase activity of the intestinal mucosa in celiac disease. Scandinavian Journal of Gastroenterology. 1974;9(3):255-259. Not sensitivity or specificity of an identified test. [pmid: 4854843].
Jalava T, Maki M, Marttinen A, et al. The in vitro response to human fibroblast-derived extracellular matrix proteins is restricted by specific HLA class II genes. Relevance for coeliac disease. Hum Immunol. 1996;49(2):106-112. Not sensitivity or specificity of an identified test. [pmid: 8872164].
Jalkanen S, Saari S, Kalimo H, et al. Lymphocyte migration into the skin: The role of lymphocyte homing receptor (CD44) and endothelial cell antigen (HECA-452). J Invest Dermatol. 1990;94(6):786-792. Not sensitivity or specificity of an identified test. [pmid: 1693939].
James M W, Scott B B. Coeliac disease: the cause of the various associated disorders?. European Journal of Gastroenterology & Hepatology. 2001;13(9):1119-1121. Not sensitivity or specificity of an identified test. [pmid: 11564967].
James M W, Scott B B. Evidence-based clinical medicine: Application of a diagnostic test using the example of coeliac disease. Cme J Gastroenterol Hepatol Nutr. 2001;4(1):28-31. Not sensitivity or specificity of an identified test.
Janatkova I, Malic caron, Fu caron, et al. Diagnostic asset of assessment of autoantibodies in gluten-sensitive enteropathy. Epidemiol Mikrobiol Imunol. 2002;51(3):125-130. Not sensitivity or specificity of an identified test. [pmid: 12184191].
Janatuinen E K, Kemppainen T A, Julkunen R J K, et al. No harm from five year ingestion of oats in coeliac disease. Gut. 2002;50(3):332-335. Not sensitivity or specificity of an identified test. [pmid: 11839710]. [pmcid: 1773136].
Janatuinen E K, Kemppainen T A, Pikkarainen P H, et al. Lack of cellular and humoral immunological responses to oats in adults with coeliac disease. Gut. 2000;46(3):327-331. Not sensitivity or specificity of an identified test. [pmid: 10673292]. [pmcid: 1727854].
Janatuinen E K, Pikkarainen P H, Kemppainen T A, et al. A comparison of diets with and without oats in adults with celiac disease. New England Journal of Medicine. 1995;333(16):1033-1037. Not sensitivity or specificity of an identified test. [pmid: 7675045].
Jansen Th T L A, Mulder C J J, Karssen P H Z, et al. Epidemiological survey of the Dutch Coeliac Disease Society: An update 1992. European Journal of Gastroenterology & Hepatology. 1993;5(2):73-78. Not sensitivity or specificity of an identified test.
Jansen J W, Haverkate F, Koopman J, et al. Influence of factor XIIIa activity on human whole blood clot lysis in vitro. Thrombosis and Haemostasis. 1987;57(2):171-175. Not sensitivity or specificity of an identified test. [pmid: 2440124].
Jansson Ulf H G, Kristiansson Bengt, Albertsson-Wikland Kerstin, et al. Short-term gluten challenge in children with coeliac disease does not impair spontaneous growth hormone secretion. Journal of Pediatric Endocrinology & Metabolism - Jpem. 2003;16(5):771-778. Not sensitivity or specificity of an identified test. [pmid: 12880127].
Jansson U, Johansson C. Down syndrome and celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1995;21(4):443-445. Not sensitivity or specificity of an identified test. [pmid: 8583297].
Jansson U H, Gudjonsdottir A H, Ryd W, et al. Two different doses of gluten show a dose-dependent response of enteropathy but not of serological markers during gluten challenge in children with coeliac disease. Acta Paediatrica (Oslo, Norway - 1992). 2001;90(3):255-259. Not sensitivity or specificity of an identified test. [pmid: 11332163].
Jarnik M, Kartasova T, Steinert P M, et al. Differential expression and cell envelope incorporation of small proline-rich protein 1 in different cornified epithelia. Journal of Cell Science. 1996;109(Pt 6):1381-1391. Not sensitivity or specificity of an identified test. [pmid: 8799826].
Jarvinen Teea T, Kaukinen Katri, Laurila Kaija, et al. Intraepithelial lymphocytes in celiac disease. American Journal of Gastroenterology. 2003;98(6):1332-1337. Unable to extract data. [pmid: 12818278].
Jaskowski T D, Schroder C, Martins T B, et al. IgA antibodies against endomysium and transglutaminase: a comparison of methods. Journal of Clinical Laboratory Analysis. 2001;15(3):108-111. Improper control group. [pmid: 11344523].
Jeffries G H, Steinberg H, Sleisenger M H. Chronic ulcerative (nongranulomatous) jejunitis. American Journal of Medicine. 1968;44(1):47-59. Not sensitivity or specificity of an identified test. [pmid: 5635287].
Jeitner T M, Bogdanov M B, Matson W R, et al. N(epsilon)-(gamma-L-glutamyl)-L-lysine (GGEL) is increased in cerebrospinal fluid of patients with Huntington's disease. Journal of Neurochemistry. 2001;79(5):1109-1112. Not sensitivity or specificity of an identified test. [pmid: 11739625].
Jelinkova L, Tuckova L, Sanchez D, et al. Increased levels of circulating ICAM-1, E-selectin, and IL-2 receptors in celiac disease. Digestive Diseases and Sciences. 2000;45(2):398-402. Not sensitivity or specificity of an identified test. [pmid: 10711458].
Jenkins D J A, Taylor R H, Wolever T M S. The diabetic diet, dietary carbohydrate and differences in digestibility. Diabetologia. 1982;23(6):477-484. Not sensitivity or specificity of an identified test. [pmid: 6295862].
Jenkins D, Goodall A, Scott B. T-cell and plasma cell populations in coeliac small intestinal mucosa in relation to dermatitis herpetiformis. Gut. 1989;30(7):955-958. Not sensitivity or specificity of an identified test. [pmid: 2788114]. [pmcid: 1434300].
Jenkins D, Goodall A, Scott B B. T-lymphocyte populations in normal and coeliac small intestinal mucosa defined by monoclonal antibodies. Gut. 1986;27(11):1330-1337. Not sensitivity or specificity of an identified test. [pmid: 3491776]. [pmcid: 1434057].
Jennings J S R, Howdle P D. Celiac disease. Curr Opin Gastroenterol. 2001;17(2):118-126. Not sensitivity or specificity of an identified test. [pmid: 11224666].
Jennings J S R, Howdle P D. New developments in celiac disease. Curr Opin Gastroenterol. 2003;19(2):118-129. Not sensitivity or specificity of an identified test. [pmid: 15703551].
Jennings W, Rowland R, Hecker R. The significance of lowered jejunal disaccharidase levels. Australian and New Zealand Journal of Medicine. 1976;6(6):556-560. Not sensitivity or specificity of an identified test. [pmid: 1071540].
Jensen K, Sollid L M, Scott H, et al. Gliadin-specific T cell responses in peripheral blood of healthy individuals involve T cells restricted by the coeliac disease associated DQ2 heterodimer. Scandinavian Journal of Immunology. 1995;42(1):166-170. Not sensitivity or specificity of an identified test. [pmid: 7543212].
Jensen M L, Johansen P. Immunocytochemical staining of smears and corresponding cell blocks from serous effusions: a follow-up and comparative investigation. Diagnostic Cytopathology. 1996;15(1):33-36. Not sensitivity or specificity of an identified test. [pmid: 8807249].
Jensen P H, Lorand L, Ebbesen P, et al. Type-2 plasminogen-activator inhibitor is a substrate for trophoblast transglutaminase and factor XIIIa. Transglutaminase-catalyzed cross-linking to cellular and extracellular structures. European Journal of Biochemistry / Febs. 1993;214(1):141-146. Not sensitivity or specificity of an identified test. [pmid: 8099547].
Jeong J M, Murthy S N, Radek J T, et al. The fibronectin-binding domain of transglutaminase. Journal of Biological Chemistry. 1995;270(10):5654-5658. Not sensitivity or specificity of an identified test. [pmid: 7890687].
Jeppesen P B, Mortensen P B. The influence of a preserved colon on the absorption of medium chain fat in patients with small bowel resection. Gut. 1998;43(4):478-483. Not sensitivity or specificity of an identified test. [pmid: 9824602]. [pmcid: 1727269].
Jessen B A, Phillips M A, Hovnanian A, et al. Role of Sp1 response element in transcription of the human transglutaminase 1 gene. Journal of Investigative Dermatology. 2000;115(1):113-117. Not sensitivity or specificity of an identified test. [pmid: 10886517].
Jessurun J, Yardley J H, Giardiello F M, et al. Chronic colitis with thickening of the subepithelial collagen layer (collagenous colitis): histopathologic findings in 15 patients. Human Pathology. 1987;18(8):839-848. Not sensitivity or specificity of an identified test. [pmid: 3610134].
Jevon G P, Dimmick J E, Dohil R, et al. Spectrum of gastritis in celiac disease in childhood. Pediatric and Developmental Pathology - the Official Journal of the Society for Pediatric Pathology and the Paediatric Pathology Society. 1999;2(3):221-226. Not sensitivity or specificity of an identified test. [pmid: 10191345].
Jewell D P. Celiac disease. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 2000;14(8):665-666. Not sensitivity or specificity of an identified test. [pmid: 11185528].
Jiang H, Kochhar D M. Induction of tissue transglutaminase and apoptosis by retinoic acid in the limb bud. Teratology. 1992;46(4):333-340. Not sensitivity or specificity of an identified test. [pmid: 1357767].
Jing Y, Waxman S, Lopez R. The cellular retinoic acid binding protein II is a positive regulator of retinoic acid signaling in breast cancer cells. Cancer Research. 1997;57(9):1668-1672. Not sensitivity or specificity of an identified test. [pmid: 9135005].
Jiskra J, Limanova Z, Vanic caron, et al. IgA and IgG antigliadin, IgA anti-tissue transglutaminase and antiendomysial antibodies in patients with autoimmune thyroid diseases and their relationship to thyroidal replacement therapy. Physiol Res. 2003;52(1):79-88. Not sensitivity or specificity of an identified test. [pmid: 12625811].
Jodl J, Stepan J, Lojda Z. Diagnostic significance of determination of serum alkaline phosphatase intestinal isoenzyme activity in coeliac sprue in childhood. Acta Universitatis Carolinae.Medica. Monographia. 1977;78 Pt:265-70. Not sensitivity or specificity of an identified test.
Johansen B H, Buus S, Vartdal F, et al. Binding of peptides to HLA-DQ molecules: peptide binding properties of the disease-associated HLA-DQ(alpha 1*0501, beta 1*0201) molecule. International Immunology. 1994;6(3):453-461. Not sensitivity or specificity of an identified test. [pmid: 8186196].
Johansen B H, Gjertsen H A, Vartdal F, et al. Binding of peptides from the N-terminal region of alpha-gliadin to the celiac disease-associated HLA-DQ2 molecule assessed in biochemical and T cell assays. Clinical Immunology and Immunopathology. 1996;79(3):288-293. Not sensitivity or specificity of an identified test. [pmid: 8635288].
Johansen B H, Jensen T, Thorpe C J, et al. Both alpha and beta chain polymorphisms determine the specificity of the disease-associated HLA-DQ2 molecules, with beta chain residues being most influential. Immunogenetics. 1996;45(2):142-150. Not sensitivity or specificity of an identified test. [pmid: 8952964].
Johansen B H, Vartdal F, Eriksen J A, et al. Identification of a putative motif for binding of peptides to HLA-DQ2. International Immunology. 1996;8(2):177-182. Not sensitivity or specificity of an identified test. [pmid: 8671602].
Johansson L, Andersson C, Albin M. Immunohistochemical study of 158 lung carcinomas. Apmis - Acta Pathologica, Microbiologica, Et Immunologica Scandinavica. 1992;100(10):914-921. Not sensitivity or specificity of an identified test. [pmid: 1280149].
Johansson S, Lie B A, Cambon-Thomsen A, et al. No evidence of type 1 diabetes susceptibility genes in the region centromeric of the HLA complex. Hum Immunol. 2003;64(10):951-959. Not sensitivity or specificity of an identified test. [pmid: 14522092].
Johansson S, Lie B A, Pociot F, et al. HLA associations in type 1 diabetes: DPB1 alleles may act as markers of other HLA-complex susceptibility genes. Tissue Antigens. 2003;61(5):344-351. Not sensitivity or specificity of an identified test. [pmid: 12753653].
Johnson G V W, Bailey C D C, Tucholski J, et al. Tissue transglutaminase in neurodegenerative diseases. Minerva Biotecnol. 2002;14(2):171-176. Not sensitivity or specificity of an identified test.
Johnson G V, Cox T M, Lockhart J P, et al. Transglutaminase activity is increased in Alzheimer's disease brain. Brain Research. 1997;751(2):323-329. Not sensitivity or specificity of an identified test. [pmid: 9099822].
Johnson K, Hashimoto S, Lotz M, et al. Interleukin-1 induces pro-mineralizing activity of cartilage tissue transglutaminase and factor XIIIa. American Journal of Pathology. 2001;159(1):149-163. Not sensitivity or specificity of an identified test. [pmid: 11438463]. [pmcid: 1850418].
Johnson T N, Tanner M S, Taylor C J, et al. Enterocytic CYP3A4 in a paediatric population: Developmental changes and the effect of coeliac disease and cystic fibrosis. Br J Clin Pharmacol. 2001;51(5):451-460. Not sensitivity or specificity of an identified test. [pmid: 11422003]. [pmcid: 2014473].
Johnson T S, El Koraie A F, Skill N J, et al. Tissue transglutaminase and the progression of human renal scarring. J Am Soc Nephrol. 2003;14(8):2052-2062. Not sensitivity or specificity of an identified test. [pmid: 12874459].
Johnson T S, Griffin M, Thomas G L, et al. The role of transglutaminase in the rat subtotal nephrectomy model of renal fibrosis. J Clin Invest. 1997;99(12):2950-2960. Not sensitivity or specificity of an identified test. [pmid: 9185519]. [pmcid: 508147].
Johnson T S, Knight C R, el Alaoui S, et al. Transfection of tissue transglutaminase into a highly malignant hamster fibrosarcoma leads to a reduced incidence of primary tumour growth. Oncogene. 1994;9(10):2935-2942. Not sensitivity or specificity of an identified test. [pmid: 7916148].
Johnston C F, Bell P M, Collins B J, et al. Reassessment of enteric endocrine cell hyperplasia in celiac disease. Hepato-Gastroenterology. 1988;35(6):285-288. Unable to extract data. [pmid: 3215624].
Johnston S D, Watson R G P. Small bowel lymphoma in unrecognized coeliac disease: A cause for concern?. European Journal of Gastroenterology & Hepatology. 2000;12(6):645-648. Not sensitivity or specificity of an identified test. [pmid: 10912485].
Johnston S D, Peter Watson R G, McMillan S A. Soda bread provocation test for subjects with transient serology for coeliac disease 3 years after a population screening survey. European Journal of Gastroenterology & Hepatology. 2000;12(9):1013-1015. Not sensitivity or specificity of an identified test. [pmid: 11007138].
Johnston S D, Ritchie C, Robinson J. Application of red cell distribution width to screening for coeliac disease in insulin-dependent diabetes mellitus. Irish Journal of Medical Science. 1999;168(3):167-170. Not sensitivity or specificity of an identified test. [pmid: 10540781].
Johnston S D, Smye M, Watson R P. Intestinal permeability tests in coeliac disease. Clinical Laboratory. 2001;47(34):143-150. Not sensitivity or specificity of an identified test. [pmid: 11294577].
Johnston S D, Watson R G, McMillan S A, et al. Serological markers for coeliac disease: changes with time and relationship to enteropathy. European Journal of Gastroenterology & Hepatology. 1998;10(3):259-264. Not sensitivity or specificity of an identified test. [pmid: 9585032].
Johnston S D, Watson R G, McMillan S A et al. Preliminary results from follow-up of a large-scale population survey of antibodies to gliadin, reticulin and endomysium. Acta paediatrica (Oslo, Norway : 1992).Supplement. 1996;41261–64. Not sensitivity or specificity of an identified test
Johnston S D, Watson R G, McMillan S A, et al. Coeliac disease detected by screening is not silent--simply unrecognized. Qjm - Monthly Journal of the Association of Physicians. 1998;91(12):853-860. Not sensitivity or specificity of an identified test. [pmid: 10024951].
Johnston S D, Watson R G, Middleton D, et al. Genetic, morphometric and immunohistochemical markers of latent coeliac disease. European Journal of Gastroenterology & Hepatology. 1999;11(11):1283-1288. Unable to extract data. [pmid: 10563541].
Johnston Simon D, McMillan Stanley A, Collins John S, et al. A comparison of antibodies to tissue transglutaminase with conventional serological tests in the diagnosis of coeliac disease. European Journal of Gastroenterology & Hepatology. 2003;15(9):1001-1004. Improper control group. [pmid: 12923373].
Jois J, Omagari K, Rowley M J, et al. Enzyme inhibitory antibody to pyruvate dehydrogenase: diagnostic utility in primary biliary cirrhosis. Annals of Clinical Biochemistry. 2000;37(Pt 1):67-73. Not sensitivity or specificity of an identified test. [pmid: 10672375].
Jokinen J, Peters U, Maki M, et al. Celiac sprue in patients with chronic oral mucosal symptoms. Journal of Clinical Gastroenterology. 1998;26(1):23-26. Not sensitivity or specificity of an identified test. [pmid: 9492858].
Jonas A. Significance of HLA expression in the mucosa of patients with active celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1987;6(5):821-822. Not sensitivity or specificity of an identified test. [pmid: 3681586].
Jones J G, Elmes M E. The measurement of mucosal non-myelinated nerve fibre area and endocrine cell area in coeliac disease using morphometric analysis. Diagnostic Histopathology / Published in Association With the Pathological Society of Great Britain and Ireland. 1982;5(3):183-188. Not sensitivity or specificity of an identified test. [pmid: 7140504].
Jones P E, Gleeson M H. Mucosal ulceration and mesenteric lymphadenopathy in coeliac disease. British Medical Journal. 1973;3(5873):212-213. Not sensitivity or specificity of an identified test. [pmid: 4753253]. [pmcid: 1586301].
Jones P E, Peters T J. DNA synthesis by jejunal mucosa in responsive and non-responsive coeliac disease. British Medical Journal. 1977;1(6069):1130-1131. Not sensitivity or specificity of an identified test. [pmid: 861498]. [pmcid: 1606647].
Jones P E, L'Hirondel C L, Peters T J. Protein synthesis by cultured jejunal mucosa from control subjects and patients with coeliac disease. Gut. 1981;22(8):623-627. Not sensitivity or specificity of an identified test. [pmid: 7286778]. [pmcid: 1420058].
Jones P E, L'Hirondel C, Peters T J. Alkaline phosphatase synthesis and properties of subcellular organelles during in vitro culture of jejunal biopsies from control subjects and patients with coeliac disease. Gut. 1982;23(2):108-114. Not sensitivity or specificity of an identified test. [pmid: 7068034]. [pmcid: 1419552].
Jones P E, Pallis C, Peters T J. Morphological and biochemical findings in jejunal biopsies from patients with multiple sclerosis. Journal of Neurology, Neurosurgery, and Psychiatry. 1979;42(5):402-406. Not sensitivity or specificity of an identified test. [pmid: 448378].
Jones R A, Nicholas B, Mian S, et al. Reduced expression of tissue transglutaminase in a human endothelial cell line leads to changes in cell spreading, cell adhesion and reduced polymerisation of fibronectin. Journal of Cell Science. 1997;110(Pt 19):2461-2472. Not sensitivity or specificity of an identified test. [pmid: 9410884].
Jordan S C, Sakai R S, Ettenger R B, et al. Characterization of soluble circulating immune complexes by antigen-specific dissociation. Detection in the Raji cell radioimmune assay. Clin Immunol Immunopathol. 1983;27(3):357-368. Not sensitivity or specificity of an identified test. [pmid: 6191904].
Jos J, Labbe F. Ultrastructural localization of IgA globulins in normal and coeliac intestinal mucosa using immunoenzymatic methods. Biomedicine / Publiee Pour L'a.a.i.c.i.g. 1976;24(6):425-434. Not sensitivity or specificity of an identified test. [pmid: 798608].
Jos J, Labbe F, Geny B, et al. Immunoelectron-microscopic localization of immunoglobulin A and secretory component in jejunal mucosa from children with coeliac disease. Scandinavian Journal of Immunology. 1979;9(5):441-450. Not sensitivity or specificity of an identified test. [pmid: 379983].
Jos J, Lenoir G, Ritis G, et al. In vitro pathogenetic studies of coeliac disease. Effects of protein digests on coeliac intestinal biopsy specimens maintained in culture for 48 hours. Scandinavian Journal of Gastroenterology. 1975;10(2):121-128. Not sensitivity or specificity of an identified test. [pmid: 1091964].
Joseph B, Lefebvre O, Mereau-Richard C, et al. Evidence for the involvement of both retinoic acid receptor- and retinoic X receptor-dependent signaling pathways in the induction of tissue transglutaminase and apoptosis in the human myeloma cell line RPMI 8226. Blood. 1998;91(7):2423-2432. Not sensitivity or specificity of an identified test. [pmid: 9516142].
Joseph Bertrand, Marchetti Philippe, Lefebvre Olga, et al. The novel retinoid AHPN/CD437 induces a rapid but incomplete apoptotic response in human myeloma cells. Biochimica Et Biophysica Acta. 2003;1593(23):277-282. Not sensitivity or specificity of an identified test. [pmid: 12581872].
Joventino L P, Stock W, Lane N J, et al. Certain HLA antigens are associated with specific morphologic and cytogenetic subsets of acute myeloid leukemia. Leukemia. 1995;9(3):433-439. Not sensitivity or specificity of an identified test. [pmid: 7885042].
Juby L D, Dixon M F, Axon A T. Abnormal intestinal permeability and jejunal morphometry. Journal of Clinical Pathology. 1987;40(7):714-718. Not sensitivity or specificity of an identified test. [pmid: 3114327]. [pmcid: 1141086].
Juby L D, Rothwell J, Axon A T. Cellobiose/mannitol sugar test--a sensitive tubeless test for coeliac disease: results on 1010 unselected patients. Gut. 1989;30(4):476-480. Not sensitivity or specificity of an identified test. [pmid: 2497056]. [pmcid: 1434034].
Juby L D, Rothwell J, Axon A T. Lactulose/mannitol test: an ideal screen for celiac disease. Gastroenterology. 1989;96(1):79-85. Not sensitivity or specificity of an identified test. [pmid: 2491824].
Julkunen H, Siren M-K, Kaaja R, et al. Maternal HLA antigens and antibodies to SS-A/RO and SS-B/LA. Comparison with systemic lupus erythematosus and primary Sjogren's syndrome. Br J Rheumatol. 1995;34(10):901-907. Not sensitivity or specificity of an identified test. [pmid: 7582692].
Jung G, Fleckenstein B, von der, et al. From combinatorial libraries to MHC ligand motifs, T-cell superagonists and antagonists. Biologicals - Journal of the International Association of Biological Standardization. 2001;29(34):179-181. Not sensitivity or specificity of an identified test. [pmid: 11851313].
Junn Eunsung, Ronchetti Ruben D, Quezado Martha M, et al. Tissue transglutaminase-induced aggregation of alpha-synuclein: Implications for Lewy body formation in Parkinson's disease and dementia with Lewy bodies. Proceedings of the National Academy of Sciences of the United States of America. 2003;100(4):2047-2052. Not sensitivity or specificity of an identified test. [pmid: 12576551]. [pmcid: 149956].
Jurado A, Cardaba B, Jara P, et al. Autoimmune hepatitis type 2 and hepatitis C virus infection: Study of HLA antigens. J Hepatol. 1997;26(5):983-991. Not sensitivity or specificity of an identified test. [pmid: 9186828].
Jurgensen K, Aeschlimann D, Cavin V, et al. A new biological glue for cartilage-cartilage interfaces: Tissue transglutaminase. J Bone Jt Surg Ser A. 1997;79(2):185-193. Not sensitivity or specificity of an identified test.
Just J J. Genetic predisposition to HIV-1 infection and acquired immune deficiency virus syndrome: A review of the literature examining associations with HLA. Hum Immunol. 1995;44(3):156-169. Not sensitivity or specificity of an identified test. [pmid: 8666552].
Juto P, Fredrikzon B, Hernell O. Gliadin-specific serum immunoglobulins A, E, G, and M in childhood: relation to small intestine mucosal morphology. Journal of Pediatric Gastroenterology and Nutrition. 1985;4(5):723-729. Not sensitivity or specificity of an identified test. [pmid: 4045630].
Kaczmarek E, Liu Y, Berse B, et al. Biosynthesis of plasma factor XIII: evidence for transcription and translation in hepatoma cells. Biochimica Et Biophysica Acta. 1995;1247(1):127-134. Not sensitivity or specificity of an identified test. [pmid: 7873582].
Kaczmarski M. The disaccharidase activity of jejunal mucosa in children with malabsorption syndrome caused by food intolerance. Roczniki Akademii Medycznej W Bialymstoku (1995). 1995;40(3):504-511. Not sensitivity or specificity of an identified test. [pmid: 8775328].
Kadokawa Y, Omagari K, Hazama H, et al. Evaluation of newly developed ELISA using “MESACUP-2 Test Mitochondrial M2” kit for the diagnosis of primary biliary cirrhosis. Clin Biochem. 2003;36(3):203-210. Not sensitivity or specificity of an identified test. [pmid: 12726929].
Kadunce D P, McMurry M P, Avots-Avotins A, et al. The effect of an elemental diet with and without gluten on disease activity in dermatitis herpetiformis. Journal of Investigative Dermatology. 1991;97(2):175-182. Not sensitivity or specificity of an identified test. [pmid: 2071933].
Kadunce D P, Meyer L J, Zone J J. IgA class antibodies in dermatitis herpetiformis: reaction with tissue antigens. Journal of Investigative Dermatology. 1989;93(2):253-258. Not sensitivity or specificity of an identified test. [pmid: 2474032].
Kagnoff M F. Coeliac disease: genetic, immunological and environmental factors in disease pathogenesis. Scandinavian Journal of Gastroenterology.Supplement 1985;11445–54. Not sensitivity or specificity of an identified test
Kagnoff M F. Immunopathogenesis of celiac disease. Immunological Investigations. 1989;18(14):499-508. Not sensitivity or specificity of an identified test. [pmid: 2659519].
Kagnoff M F. Understanding the molecular basis of coeliac disease. Gut. 1990;31(5):497-499. Not sensitivity or specificity of an identified test. [pmid: 2112501]. [pmcid: 1378560].
Kagnoff M F, Harwood J I, Bugawan T L, et al. Structural analysis of the HLA-DR, -DQ, and -DP alleles on the celiac disease-associated HLA-DR3 (DRw17) haplotype. Proceedings of the National Academy of Sciences of the United States of America. 1989;86(16):6274-6278. Not sensitivity or specificity of an identified test. [pmid: 2788285]. [pmcid: 297820].
Kagnoff M F, Weiss J B, Brown R J, et al. Immunoglobulin allotype markers in gluten-sensitive enteropathy. Lancet. 1983;1(8331):952-953. Not sensitivity or specificity of an identified test. [pmid: 6132268].
Kagnoff Martin F. Celiac disease pathogenesis: the plot thickens. Gastroenterology. 2002;123(3):939-943. Not sensitivity or specificity of an identified test. [pmid: 12198718].
Kahn H J, Fekete E, From L. Tenascin differentiates dermatofibroma from dermatofibrosarcoma protuberans: comparison with CD34 and factor XIIIa. Human Pathology. 2001;32(1):50-56. Not sensitivity or specificity of an identified test. [pmid: 11172295].
Kainulainen H, Rantala I, Collin P, et al. Blisters in the small intestinal mucosa of coeliac patients contain T cells positive for cyclooxygenase 2. Gut. 2002;50(1):84-89. Not sensitivity or specificity of an identified test. [pmid: 11772972]. [pmcid: 1773065].
Kakar S, Nehra V, Murray J A, et al. Significance of intraepithelial lymphocytosis in small bowel biopsy samples with normal mucosal architecture. American Journal of Gastroenterology. 2003;98(9):2027-2033. Not sensitivity or specificity of an identified test. [pmid: 14499783].
Kalapesi Z, Rees J P R. Coeliac disease in schoolchildren. Ir Med J. 1978;71(6):188-191. Not sensitivity or specificity of an identified test. [pmid: 649327].
Kallikorm R, Uibo O, Uibo R. Coeliac disease in spondyloarthropathy: usefulness of serological screening. Clinical Rheumatology. 2000;19(2):118-122. Not sensitivity or specificity of an identified test. [pmid: 10791622].
Kalogeropoulos C D, Spyrou P, Stefaniotou M I, et al. Anticardiolipin antibodies and occlusive vascular disease of the eye: prospective study. Documenta Ophthalmologica. Advances in Ophthalmology. 1998;95(2):109-120. Not sensitivity or specificity of an identified test. [pmid: 10431795].
Kandel L B, Whyard T C, Gonder M J. Monoclonal antibody identification of a potentially lithogenic protein extracted from human renal calculi. Journal of Stone Disease. 1992;4(4):283-288. Not sensitivity or specificity of an identified test. [pmid: 10147809].
Kanerud L, Engstrom G N, Tarkowski A. Evidence for differential effects of sulphasalazine on systemic and mucosal immunity in rheumatoid arthritis. Annals of the Rheumatic Diseases. 1995;54(4):256-262. Not sensitivity or specificity of an identified test. [pmid: 7763101]. [pmcid: 1005570].
Kanitakis J, Roca-Miralles M. Factor-XIIIa-expressing dermal dendrocytes in Kaposi's sarcoma. A comparison between classical and immunosuppression-associated types. Virchows Archiv. A, Pathological Anatomy and Histopathology. 1992;420(3):227-231. Not sensitivity or specificity of an identified test.
Kanungo A, Samal K C, Sanjeevi C B. Molecular mechanisms involved in the etiopathogenesis of malnutrition-modulated diabetes mellitus. Annals of the New York Academy of Sciences 2002;958138–143. Not sensitivity or specificity of an identified test
Kanungo A, Shtauvere-Brameus A, Samal K C et al. Autoantibodies to tissue transglutaminase in patients from eastern India with malnutrition-modulated diabetes mellitus, insulin-dependent diabetes mellitus, and non-insulin-dependent diabetes mellitus. Annals of the New York Academy of Sciences 2002;958232–234. Not sensitivity or specificity of an identified test
Kapadia C. The reliability of noninvasive tests for celiac disease. Gastroenterology. 1995;108(2):608-610. Review article. [pmid: 7557159].
Kapuscinska A, Zalewski T, Chorzelski T P, et al. Disease specificity and dynamics of changes in IgA class anti-endomysial antibodies in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1987;6(4):529-534. Improper control group. [pmid: 3323442].
Karagen L, Cinnamon Y, Ginsburg M, et al. Origin of primordial germ cells in the prestreak chick embryo. Dev Genet. 1996;19(4):290-301. Not sensitivity or specificity of an identified test. [pmid: 9023982].
Karagiannis J A, Priddle J D, Jewell D P. Cell-mediated immunity to a synthetic gliadin peptide resembling a sequence from adenovirus 12. Lancet. 1987;1(8538):884-886. Not sensitivity or specificity of an identified test. [pmid: 2882290].
Karagiozoglou-Lampoudi T, Nousia-Arvanitaki S, Augoustidou-Savopoulou P, et al. Insulin secretion decline unrelated to jejunal morphology or exocrine pancreatic function in children with celiac disease. J Pediatr Endocrinol Metab. 1996;9(6):585-591. Not sensitivity or specificity of an identified test. [pmid: 9004173].
Karban A, Lerner A, Shapiro S. Th1/Th2 cytokine profile in celiac disease. Israel Journal of Medical Sciences. 1997;33(3):209-214. Not sensitivity or specificity of an identified test. [pmid: 9313792].
Karczewska K, Lukasik M, Kasner J, et al. Familial occurrence of celiac disease and isolated immunoglobulin a deficiency. Med Sci Monit. 1998;4(5):836-839. Not sensitivity or specificity of an identified test.
Karell K, Holopainen P, Mustalahti K, et al. Not all HLA DR3 DQ2 haplotypes confer equal susceptibility to coeliac disease: transmission analysis in families. Scandinavian Journal of Gastroenterology. 2002;37(1):56-61. Improper control group. [pmid: 11843036].
Karell K, Korponay-Szabo I, Szalai Zs, et al. Genetic dissection between coeliac disease and dermatitis herpetiformis in sib pairs. Annals of Human Genetics. 2002;66(Pt 56):387-392. Not sensitivity or specificity of an identified test. [pmid: 12485471].
Karell K, Louka A S, Moodie S J, et al. HLA types in celiac disease patients not carrying the DQA1 *05-DQB1 *02 (DQ2) heterodimer: Results from the European genetics cluster on celiac disease. Hum Immunol. 2003;64(4):469-477. Improper control group. [pmid: 12651074].
Kari J A, Sinnott P, Khan H, et al. Familial steroid-responsive nephrotic syndrome and HLA antigens in Bengali children. Pediatr Nephrol. 2001;16(4):346-349. Not sensitivity or specificity of an identified test. [pmid: 11354779].
Kariniemi A L, Forsman L, Wahlstrom T, et al. Expression of differentiation antigens in mammary and extramammary Paget's disease. British Journal of Dermatology. 1984;110(2):203-210. Not sensitivity or specificity of an identified test. [pmid: 6320859].
Karlsson I J, Dahl M G C, Marks J M. Absence of cutaneous IgA in coeliac disease without dermatitis herpetiformis. Br J Dermatol. 1978;99(6):621-625. Not sensitivity or specificity of an identified test. [pmid: 367420].
Karpati S, Burgin-Wolff A, Krieg T, et al. Binding to human jejunum of serum IgA antibody from children with coeliac disease. Lancet. 1990;336(8727):1335-1338. Not sensitivity or specificity of an identified test. [pmid: 1978162].
Karpati S, Kosnai I, Torok E, et al. Immunoglobulin A deposition in jejunal mucosa of children with dermatitis herpetiformis. J Invest Dermatol. 1988;91(4):336-339. Not sensitivity or specificity of an identified test. [pmid: 3049830].
Karpati S, Kosnai I, Verkasalo M, et al. HLA antigens, jejunal morphology and associated diseases in children with dermatitis herpetiformis. Acta Paediatrica Scandinavica. 1986;75(2):297-301. Not sensitivity or specificity of an identified test. [pmid: 3962661].
Karpati S, Meurer M, Stolz W, et al. Ultrastructural binding sites of endomysium antibodies from sera of patients with dermatitis herpetiformis and coeliac disease. Gut. 1992;33(2):191-193. Not sensitivity or specificity of an identified test. [pmid: 1541414]. [pmcid: 1373928].
Karpati S, Stolz W, Meurer M, et al. Extracellular binding sites of IgA anti-jejunal antibodies on normal small bowel detected by indirect immunoelectronmicroscopy. Journal of Investigative Dermatology. 1991;96(2):228-233. Not sensitivity or specificity of an identified test. [pmid: 1899445].
Karska K, Tuckova L, Steiner L, et al. Calreticulin--the potential autoantigen in celiac disease. Biochemical and Biophysical Research Communications. 1995;209(2):597-605. Not sensitivity or specificity of an identified test. [pmid: 7733929].
Kartasova T, Darwiche N, Kohno Y, et al. Sequence and expression patterns of mouse SPR1: Correlation of expression with epithelial function. Journal of Investigative Dermatology. 1996;106(2):294-304. Not sensitivity or specificity of an identified test. [pmid: 8601731].
Kashima K, Yokoyama S, Daa T, et al. Immunohistochemical study on tissue transglutaminase and copper-zinc superoxide dismutase in human myocardium: its relevance to apoptosis detected by the nick end labelling method. Virchows Archiv - an International Journal of Pathology. 1997;430(4):333-338. Not sensitivity or specificity of an identified test. [pmid: 9134045].
Kasner J, Karczewska K, Sulej J, et al. Diagnostic value of tissue transglutaminase antibodies ((dagger)TG) in celiac disease. Pediatr Wspolczesna. 2002;4(3):269-272. Unable to obtain full article.
Katona E, Haramura G, Karpati L, et al. A simple, quick one-step ELISA assay for the determination of complex plasma factor XIII (A2B2). Thrombosis and Haemostasis. 2000;83(2):268-273. Not sensitivity or specificity of an identified test. [pmid: 10739385].
Katz A J, Falchuk Z M. Definitive diagnosis of gluten-sensitive enteropathy. Use of an in vitro organ culture model. Gastroenterology. 1978;75(4):695-700. Not sensitivity or specificity of an identified test. [pmid: 710838].
Katz A J, Falchuk Z M. Current concepts in gluten sensitive enteropathy (celiac sprue). Pediatric Clinics of North America. 1975;22(4):767-785. Not sensitivity or specificity of an identified test. [pmid: 1105361].
Katz A J, Falchuk Z M, Schwachman H. The coexistence of cystic fibrosis and celiac disease. Pediatrics. 1976;57(5):715-721. Not sensitivity or specificity of an identified test. [pmid: 940712].
Katz A J, Falchuk Z M, Strober W, et al. Gluten-sensitive enteropathy. Inhibition by cortisol of the effect of gluten protein in vitro. New England Journal of Medicine. 1976;295(3):131-135. Not sensitivity or specificity of an identified test. [pmid: 1272329].
Katz K D. Celiac Disease - Current Clinical Considerations in Treatment and Avoidance of Nutritional Deficiencies. Today's Ther Trends. 2003;21(4):379-389. Not sensitivity or specificity of an identified test.
Katz S I, Hall R P, Lawley T J, et al. Dermatitis herpetiformis: the skin and the gut. Annals of Internal Medicine. 1980;93(6):857-874. Not sensitivity or specificity of an identified test. [pmid: 7447195].
Kaufmann H J. Chylous ascites and intestinal muscular hypertrophy occurring in the course of celiac sprue. American Journal of Digestive Diseases. 1975;20(5):494-497. Not sensitivity or specificity of an identified test. [pmid: 1130376].
Kaukinen K, Collin P, Holm K, et al. Small-bowel mucosal inflammation in reticulin or gliadin antibody-positive patients without villous atrophy. Scandinavian Journal of Gastroenterology. 1998;33(9):944-949. Improper control group. [pmid: 9759950].
Kaukinen K, Collin P, Holm K, et al. Wheat starch-containing gluten-free flour products in the treatment of coeliac disease and dermatitis herpetiformis. A long-term follow-up study. Scandinavian Journal of Gastroenterology. 1999;34(2):163-169. Not sensitivity or specificity of an identified test. [pmid: 10192194].
Kaukinen K, Collin P, Mykkanen A H, et al. Celiac disease and autoimmune endocrinologic disorders. Digestive Diseases and Sciences. 1999;44(7):1428-1433. Not sensitivity or specificity of an identified test. [pmid: 10489930].
Kaukinen K, Halme L, Collin P, et al. Celiac disease in patients with severe liver disease: Gluten-free diet may reverse hepatic failure. Gastroenterology. 2002;122(4):881-888. Not sensitivity or specificity of an identified test. [pmid: 11910339].
Kaukinen K, Maki M, Partanen J, et al. Celiac disease without villous atrophy: revision of criteria called for. Digestive Diseases and Sciences. 2001;46(4):879-887. Unable to extract data. [pmid: 11330428].
Kaukinen Katri, Partanen Jukka, Maki Markku, et al. HLA-DQ typing in the diagnosis of celiac disease. American Journal of Gastroenterology. 2002;97(3):695-699. Unable to extract data. [pmid: 11922565].
Kaukinen Katri, Sulkanen Satu, Maki Markku, et al. IgA-class transglutaminase antibodies in evaluating the efficacy of gluten-free diet in coeliac disease. European Journal of Gastroenterology & Hepatology. 2002;14(3):311-315. Not sensitivity or specificity of an identified test. [pmid: 11953698].
Kaur Gurvinder, Sarkar N, Bhatnagar S, et al. Pediatric celiac disease in India is associated with multiple DR3-DQ2 haplotypes. Human Immunology. 2002;63(8):677-682. Improper control group. [pmid: 12121676].
Kavai M, Csorba S, Szabolcs M, et al. Association of precipitins and coeliac disease. Acta Allergologica. 1977;32(6):395-405. Not sensitivity or specificity of an identified test. [pmid: 413326].
Kavai M, Szabolcs M, Csorba S. Circulating antibodies in coeliac disease. Acta Paediatr Acad Sci Hung. 1977;18(34):235-238. Not sensitivity or specificity of an identified test. [pmid: 613733].
Kavin H. Adult coeliac disease in South Africa. An analysis of 20 cases emphasizing atypical presentations. S Afr Med J. 1981;59(18):628-632. Not sensitivity or specificity of an identified test. [pmid: 7221782].
Kawabe S, Ikuta T, Ohba M, et al. Cholesterol sulfate activates transcription of transglutaminase 1 gene in normal human keratinocytes. Journal of Investigative Dermatology. 1998;111(6):1098-1102. Not sensitivity or specificity of an identified test. [pmid: 9856823].
Kazerounian S, Aho S. Characterization of periphilin, a widespread, highly insoluble nuclear protein and potential constituent of the keratinocyte cornified envelope. J Biol Chem. 2003;278(38):36707-36717. Not sensitivity or specificity of an identified test. [pmid: 12853457].
Keating J, Bjarnason I, Somasundaram S, et al. Intestinal absorptive capacity, intestinal permeability and jejunal histology in HIV and their relation to diarrhoea. Gut. 1995;37(5):623-629. Not sensitivity or specificity of an identified test. [pmid: 8549936]. [pmcid: 1382865].
Kedzierska A. Immunogenetic aspects of coeliac disease in children. Med Sci Monit. 1999;5(4):732-740. Not sensitivity or specificity of an identified test.
Kedzierska A, Turowski G. HLA class I haplotypes in families of children with coeliac disease. Medical Science Monitor - International Medical Journal of Experimental and Clinical Research. 2000;6(2):336-341. Not sensitivity or specificity of an identified test. [pmid: 11208438].
Kedzierska A, Turowski G. HLA class I antigens in families with coeliac disease. Medical Science Monitor - International Medical Journal of Experimental and Clinical Research. 2000;6(5):957-963. Not sensitivity or specificity of an identified test. [pmid: 11208438].
Keeling J W, Risdon R A. Proceedings: Quantitation of small intestinal biopsies from children. Archives of Disease in Childhood. 1974;49(9):747. Not sensitivity or specificity of an identified test. [pmid: 4419427].
Kelleher D, Murphy A, Sheils O, et al. Tyrosine phosphorylation in the human duodenum. Gut. 1995;36(1):34-38. Not sensitivity or specificity of an identified test. [pmid: 7534252]. [pmcid: 1382349].
Kelly C P, Feighery C F, Gallagher R B et al. Diagnosis and treatment of gluten-sensitive enteropathy. Advances in Internal Medicine 1990;35341–363. Not sensitivity or specificity of an identified test
Kelly C P, Feighery C F, Gallagher R B, et al. Mucosal and systemic IgA anti-gliadin antibody in celiac disease. Contrasting patterns of response in serum, saliva, and intestinal secretions. Digestive Diseases and Sciences. 1991;36(6):743-751. Improper control group. [pmid: 2032515].
Kelly C P, O'Shea B, Kelly J. Atopy and childhood coeliac disease. Lancet. 1987;2(8550):109. Not sensitivity or specificity of an identified test. [pmid: 2885566].
Kelly J, O'Farrelly C, Rees J P. alpha-Gliadin antibodies in childhood coeliac disease. Lancet. 1985;2(8454):558-559. Not sensitivity or specificity of an identified test. [pmid: 2863581].
Kelly J, O'Farrelly C, O'Mahony C, et al. Immunoperoxidase demonstration of the cellular composition of the normal and coeliac small bowel. Clinical and Experimental Immunology. 1987;68(1):177-188. Not sensitivity or specificity of an identified test. [pmid: 2820630]. [pmcid: 1542674].
Kelly J, O'Farrelly C, Rees J P, et al. Humoral response to alpha gliadin as serological screening test for coeliac disease. Archives of Disease in Childhood. 1987;62(5):469-473. Serology <1990. [pmid: 3606179].
Kelly J, Weir D G, Feighery C. Differential expression of HLA-D gene products in the normal and coeliac small bowel. Tissue Antigens. 1988;31(3):151-160. Not sensitivity or specificity of an identified test. [pmid: 3376099].
Kelly J, Whelan C A, Weir D G, et al. Removal of endogenous peroxidase activity from cryostat sections for immunoperoxidase visualisation of monoclonal antibodies. Journal of Immunological Methods. 1987;96(1):127-132. Not sensitivity or specificity of an identified test. [pmid: 3100646].
Kelly M H, Hamilton J R. A micro-technique for the assay of intestinal alkaline phosphatase. Results in normal children and in children with celiac disease. Clinical Biochemistry. 1970;3(1):33-43. Not sensitivity or specificity of an identified test. [pmid: 5535710].
Kemeny D M, Urbanek R, Amlot P L, et al. Sub-class of IgG in allergic disease. I. IgG sub-class antibodies in immediate and non-immediate food allergy. Clinical Allergy. 1986;16(6):571-581. Not sensitivity or specificity of an identified test. [pmid: 3791631].
Kemppainen T A, Kosma V M, Janatuinen E K, et al. Nutritional status of newly diagnosed celiac disease patients before and after the institution of a celiac disease diet--association with the grade of mucosal villous atrophy. American Journal of Clinical Nutrition. 1998;67(3):482-487. Not sensitivity or specificity of an identified test. [pmid: 9497194].
Kemppainen T, Kroger H, Janatuinen E, et al. Bone recovery after a gluten-free diet: A 5-year follow-up study. Bone. 1999;25(3):355-360. Not sensitivity or specificity of an identified test. [pmid: 10495140].
Kennedy N P, Feighery C. Clinical features of coeliac disease today. Biomedicine & Pharmacotherapy=Biomedecine & Pharmacotherapie. 2000;54(7):373-380. Not sensitivity or specificity of an identified test.
Keogh J P, Zirvi K A, Vossough S, et al. Pharmacological alterations of cellular transglutaminase activity and invasiveness in human colorectal carcinoma cells. Cancer Biochemistry Biophysics. 1993;13(3):209-220. Not sensitivity or specificity of an identified test. [pmid: 7906610].
Kepczyk T, Kadakia S C. Prospective evaluation of gastrointestinal tract in patients with iron-deficiency anemia. Digestive Diseases and Sciences. 1995;40(6):1283-1289. Not sensitivity or specificity of an identified test. [pmid: 7781448].
Kepczyk T, Cremins J E, Long B D, et al. A prospective, multidisciplinary evaluation of premenopausal women with iron-deficiency anemia. American Journal of Gastroenterology. 1999;94(1):109-115. Not sensitivity or specificity of an identified test. [pmid: 9934740].
Kermabon C, Ehrhart A, Volant A, et al. Antigliadin antibodies in rheumatoid arthritis. Rev Rhum Engl Ed. 1993;60(3):157-161. Not sensitivity or specificity of an identified test.
Kerttula T O, Holm K, Partanen J, et al. Circulating T lymphocyte subsets in coeliac disease (CoD) patients and healthy family members. Clinical and Experimental Immunology. 1998;111(3):536-540. Not sensitivity or specificity of an identified test. [pmid: 9528895]. [pmcid: 1904878].
Kett K, Scott H, Fausa O, et al. Secretory immunity in celiac disease: Cellular expression of immunoglobulin A subclass and joining chain. Gastroenterology. 1990;99(2):386-392. Not sensitivity or specificity of an identified test. [pmid: 2194895].
Keuning J J, Pena A S, van Leeuwen A, et al. HLA-DW3 associated with coeliac disease. Lancet. 1976;1(7958):506-508. Not sensitivity or specificity of an identified test. [pmid: 55781].
Keusch G T, Jacewicz M. Primary amines and chloroquine inhibit cytotoxic responses to Shigella toxin and permit late antibody rescue of toxin treated cells. Biochemical and Biophysical Research Communications. 1984;121(1):69-76. Not sensitivity or specificity of an identified test. [pmid: 6428408].
Khoshoo V, Bhan M K, Arora N K. Gliadin antibodies for diagnosis of celiac disease. Indian Journal of Pediatrics. 1984;51(413):669-670. Not sensitivity or specificity of an identified test. [pmid: 6537404].
Khoshoo V, Bhan M K, Puri S, et al. Serum anti-gliadin antibody profile in childhood protracted diarrhoea due to coeliac disease and other causes in a developing country. Scandinavian Journal of Gastroenterology. 1989;24(10):1212-1216. Serology <1990. [pmid: 2602903].
Khoshoo V, Bhan M K, Unsworth D J, et al. Anti-reticulin antibodies: useful adjunct to histopathology in diagnosing celiac disease, especially in a developing country. Journal of Pediatric Gastroenterology and Nutrition. 1988;7(6):864-866. Not sensitivity or specificity of an identified test. [pmid: 3143820].
Khulusi S, Rhodes J. Diagnostic dilemmas in colitis. J R Coll Phys London. 1997;31(6):618-623. Not sensitivity or specificity of an identified test.
Kieffer M. Serum antibodies to gliadin and other cereal proteins in patients with coeliac disease and dermatitis herpetiformis. Danish Medical Bulletin. 1985;32(5):251-262. Not sensitivity or specificity of an identified test. [pmid: 4053695].
Kieffer M, Barnetson R S. Increased gliadin antibodies in dermatitis herpetiformis and pemphigoid. British Journal of Dermatology. 1983;108(6):673-678. Not sensitivity or specificity of an identified test. [pmid: 6344902].
Kieffer M, Barnetson StC R. What is the role of gliadin in bullous pemphigoid?. Lancet. 1981;2(8250):806. Not sensitivity or specificity of an identified test. [pmid: 6116926].
Kieffer M, Barnetson R S, Blackwell J N. Sequential studies of gliadin antibodies in patients with dermatitis herpetiformis. Archives of Dermatological Research. 1984;276(2):74-77. Not sensitivity or specificity of an identified test. [pmid: 6721574].
Kieffer M, Frazier P J, Daniels N W R. Serum antibodies (measured by MRSPAH) to alcohol-soluble gliadins in adult celiac patients. Journal of Immunological Methods. 1981;42(2):129-136. Not sensitivity or specificity of an identified test. [pmid: 7240756].
Kieslich M, Errazuriz G. Posselt H G et al. Brain white-matter lesions in celiac disease: a prospective study of 75 diet-treated patients. Pediatrics. 2001;108(2):E21. Not sensitivity or specificity of an identified test. [pmid: 11483831].
Kiguchi K, Iwamori M, Yamanouchi S, et al. Coexpression of cholesterol sulfate and cytokeratin as tumor markers in well-differentiated squamous cell carcinoma of the human uterine cervix. Clinical Cancer Research - an Official Journal of the American Association for Cancer Research. 1998;4(12):2985-2990. Not sensitivity or specificity of an identified test. [pmid: 9865910].
Kilander A F, Dotevall G, Fallstrom S P, et al. Evaluation of gliadin antibodies for detection of coeliac disease. Scandinavian Journal of Gastroenterology. 1983;18(3):377-383. Serology <1990. [pmid: 6673063].
Kilander A F, Dotevall G, Lindstedt G, et al. Plasma enteroglucagon related to malabsorption in coeliac disease. Gut. 1984;25(6):629-635. Not sensitivity or specificity of an identified test. [pmid: 6735247]. [pmcid: 1432380].
Kilander A F, Gillberg R E, Kastrup W, et al. Serum antibodies to gliadin and small-intestinal morphology in dermatitis herpetiformis. A controlled clinical study of the effect of treatment with a gluten-free diet. Scandinavian Journal of Gastroenterology. 1985;20(8):951-958. Not sensitivity or specificity of an identified test. [pmid: 3909375].
Kilander A F, Nilsson L A, Gillberg R. Serum antibodies to gliadin in coeliac disease after gluten withdrawal. Scandinavian Journal of Gastroenterology. 1987;22(1):29-34. Not sensitivity or specificity of an identified test. [pmid: 3563409].
Kilander A F, Stenhammar L, Lindstedt G, et al. Determination of enteroglucagon in plasma for detection of celiac disease in children. Clinical Chemistry. 1984;30(1):77-80. Not sensitivity or specificity of an identified test. [pmid: 6690155].
Kiljanski J I, Peele K, Stachura I, et al. Antibodies against striated muscle, connective tissue and nuclear antigens in patients with thyroid-associated ophthalmopathy: Should Graves' disease be considered a collagen disorder?. J Endocrinol Invest. 1997;20(10):585-591. Not sensitivity or specificity of an identified test. [pmid: 9438915].
Kilmartin C, Lynch S, Abuzakouk M, et al. Avenin fails to induce a TH1 response in coeliac tissue following in vitro culture. Gut. 2003;52(1):47-52. Not sensitivity or specificity of an identified test. [pmid: 12477758]. [pmcid: 1773501].
Kilpatrick Z M, Katz J. Occult celiac disease as a cause of iron deficiency anemia. Jama - the Journal of the American Medical Association. 1969;208(6):999-1001. Not sensitivity or specificity of an identified test. [pmid: 5818637].
Kim H C, Idler W W, Kim I G, et al. The complete amino acid sequence of the human transglutaminase K enzyme deduced from the nucleic acid sequences of cDNA clones. Journal of Biological Chemistry. 1991;266(1):536-539. Not sensitivity or specificity of an identified test. [pmid: 1670769].
Kim H C, Nemes Z, Idler W W, et al. Crystallization and preliminary X-ray analysis of human transglutaminase 3 from zymogen to active form. Journal of Structural Biology. 2001;135(1):73-77. Not sensitivity or specificity of an identified test. [pmid: 11562168].
Kim Hyung, Rikihisa Yasuko. Roles of p38 mitogen-activated protein kinase, NF-kappaB, and protein kinase C in proinflammatory cytokine mRNA expression by human peripheral blood leukocytes, monocytes, and neutrophils in response to Anaplasma phagocytophila. Infection and Immunity. 2002;70(8):4132-4141. Not sensitivity or specificity of an identified test. [pmid: 12117921]. [pmcid: 128199].
Kim I G, Lee S C, Lee J H, et al. Structure and organization of the human transglutaminase 3 gene: evolutionary relationship to the transglutaminase family. Journal of Investigative Dermatology. 1994;103(2):137-142. Not sensitivity or specificity of an identified test. [pmid: 7913719].
Kim I G, McBride O W, Wang M, et al. Structure and organization of the human transglutaminase 1 gene. Journal of Biological Chemistry. 1992;267(11):7710-7717. Not sensitivity or specificity of an identified test. [pmid: 1348508].
Kim S Y, Chung S I, Yoneda K, et al. Expression of transglutaminase 1 in human epidermis. Journal of Investigative Dermatology. 1995;104(2):211-217. Not sensitivity or specificity of an identified test. [pmid: 7530270].
Kim S Y, Grant P, Lee J H, et al. Differential expression of multiple transglutaminases in human brain. Increased expression and cross-linking by transglutaminases 1 and 2 in Alzheimer's disease. Journal of Biological Chemistry. 1999;274(43):30715-30721. Not sensitivity or specificity of an identified test. [pmid: 10521460].
Kim Soo, Youl Jeitner, Thomas M, et al. Transglutaminases in disease. Neurochemistry International. 2002;40(1):85-103. Not sensitivity or specificity of an identified test. [pmid: 11738475].
Kim Soo, Jeong Eun, Steinert Peter M. IFN-gamma induces transglutaminase 2 expression in rat small intestinal cells. Journal of Interferon & Cytokine Research - the Official Journal of the International Society for Interferon and Cytokine Research. 2002;22(6):677-682. Not sensitivity or specificity of an identified test. [pmid: 12162878].
Kim Y J, Park E S, Song K Y, et al. Glutathione transferase (class pi) and tissue transglutaminase (Tgase C) expression in pterygia. Korean Journal of Ophthalmology - Kjo. 1998;12(1):6-13. Not sensitivity or specificity of an identified test. [pmid: 9753945].
King A L, Ciclitira P J. Celiac disease: strongly heritable, oligogenic, but genetically complex. Molecular Genetics and Metabolism. 2000;71(12):70-75. Not sensitivity or specificity of an identified test. [pmid: 11001798].
King A L, Fraser J S, Moodie S J, et al. Coeliac disease: follow-up linkage study provides further support for existence of a susceptibility locus on chromosome 11p11. Annals of Human Genetics. 2001;65(Pt 4):377-386. Not sensitivity or specificity of an identified test. [pmid: 11592927].
King A L, Yiannakou J Y, Brett P M, et al. A genome-wide family-based linkage study of coeliac disease. Annals of Human Genetics. 2000;64(Pt 6):479-490. Not sensitivity or specificity of an identified test. [pmid: 11281212].
Kingham J G, Parker D R. The association between primary biliary cirrhosis and coeliac disease: a study of relative prevalences. Gut. 1998;42(1):120-122. Not sensitivity or specificity of an identified test. [pmid: 9577357]. [pmcid: 1726939].
Kirberg A, Latorre J J, Hartard M E. Endoscopic small intestnal biopsy in infants and children: its usefulness in the diagnosis of celiac disease and other enteropathies. Journal of Pediatric Gastroenterology and Nutrition. 1989;9(2):178-181. Not sensitivity or specificity of an identified test. [pmid: 2809937].
Kirby J, Fielding J F. Very adult coeliac disease! The need for jejunal biopsy in the middle aged and elderly. Irish Medical Journal. 1984;77(2):35-36. Not sensitivity or specificity of an identified test. [pmid: 6715139].
Kitahara A, Mikawa H, Ohtsuki H, et al. Specific localization of tissue-type transglutaminase in adrenocorticotropin-producing cells of the human pituitary gland as demonstrated by immunohistochemistry. Journal of Clinical Endocrinology and Metabolism. 1987;65(5):885-890. Not sensitivity or specificity of an identified test. [pmid: 2444616].
Kitis G, Lucas M L, Bishop H. Altered jejunal surface pH in coeliac disease: Its effect on propranolol and folic acid absorption. Clin Sci. 1982;63(4):373-380. Not sensitivity or specificity of an identified test. [pmid: 7105632].
Klaeveman H L, Gebhard R L, Sessoms C, et al. In vitro studies of ulcerative ileojejunitis. Gastroenterology. 1975;68(3):572-582. Not sensitivity or specificity of an identified test. [pmid: 1112460].
Klein M R, Keet I P M, D'Amaro J, et al. Associations between HLA frequencies and pathogenic features of human immunodeficiency virus type 1 infection in seroconverters from the Amsterdam cohort of homosexual men. J Infect Dis. 1994;169(6):1244-1249. Not sensitivity or specificity of an identified test. [pmid: 8195600].
Kleinberg-Zissin R, Avigad S, Yahav J, et al. Gluten-sensitive enteropathy: value of oral triglyceride loading test in the follow-up of patients on gluten challenge. Israel Journal of Medical Sciences. 1983;19(4):319-324. Not sensitivity or specificity of an identified test. [pmid: 6853129].
Kleman J P, Aeschlimann D, Paulsson M, et al. Transglutaminase-catalyzed cross-linking of fibrils of collagen V/XI in A204 rhabdomyosarcoma cells. Biochemistry. 1995;34(42):13768-13775. Not sensitivity or specificity of an identified test. [pmid: 7577969].
Klemetti P, Savilahti E, Ilonen J, et al. T-cell reactivity to wheat gluten in patients with insulin-dependent diabetes mellitus. Scandinavian Journal of Immunology. 1998;47(1):48-53. Not sensitivity or specificity of an identified test. [pmid: 9467658].
Klemola T. Immunohistochemical findings in the intestine of IgA-deficient persons: number of intraepithelial T lymphocytes is increased. Journal of Pediatric Gastroenterology and Nutrition. 1988;7(4):537-543. Not sensitivity or specificity of an identified test. [pmid: 3294370].
Klemola T, Savilahti E, Arato A, et al. Immunohistochemical findings in jejunal specimens from patients with IgA deficiency. Gut. 1995;37(4):519-523. Not sensitivity or specificity of an identified test. [pmid: 7489939]. [pmcid: 1382904].
Klemola T, Savilahti E, Koskimies S, et al. HLA antigens in IgA deficient paediatric patients. Tissue Antigens. 1988;32(4):218-223. Not sensitivity or specificity of an identified test. [pmid: 3217938].
Kluge F, Koch H K, Grosse-Wilde H, et al. Follow-up of treated adult celiac disease: clinical and morphological studies. Hepato-Gastroenterology. 1982;29(1):17-23. Not sensitivity or specificity of an identified test. [pmid: 7095732].
Knight C J, Sandhu B K. The investigation of chronic diarrhoea. Curr Paediatr. 2003;13(2):89-94. Not sensitivity or specificity of an identified test.
Knight C R, Rees R C, Platts A, et al. Interleukin-2-activated human effector lymphocytes mediate cytotoxicity by inducing apoptosis in human leukaemia and solid tumour target cells. Immunology. 1993;79(4):535-541. Not sensitivity or specificity of an identified test. [pmid: 8104887]. [pmcid: 1421908].
Knight R L, Hand D, Piacentini M, et al. Characterization of the transglutaminase-mediated large molecular weight polymer from rat liver: Its relationship to apoptosis. Eur J Cell Biol. 1993;60(1):210-216. Not sensitivity or specificity of an identified test. [pmid: 8096461].
Knudtzon J, Fluge G, Aksnes L. Routine measurements of gluten antibodies in children of short stature. Journal of Pediatric Gastroenterology and Nutrition. 1991;12(2):190-194. Not sensitivity or specificity of an identified test. [pmid: 2051271].
Kobayashi H, Takahashi M, Takahashi H, et al. CD4SUP+ T-cells from peripheral blood of a patient with psoriasis recognize keratin 14 peptide but not ‘homologous’ streptococcal M-protein epitope. J Dermatol Sci. 2002;30(3):240-247. Not sensitivity or specificity of an identified test. [pmid: 12443847].
Kocak N, Varzikoglu M, Yuce A, et al. Celiac disease in childhood: Analysis of 41 cases. Turk J Gastroenterol. 1997;8(2):201-205. Not sensitivity or specificity of an identified test.
Kochanska-Dziurowicz A, Bukowska C. Estimation of serum beta-2-microglobulin in children with malabsorption disorders syndrome. Journal of Gastroenterology. 1997;32(3):312-317. Not sensitivity or specificity of an identified test. [pmid: 9213243].
Kockum I, Lernmark A, Dahlquist G, et al. Genetic and immunological findings in patients with newly diagnosed insulin-dependent diabetes mellitus. The Swedish Childhood Diabetes Study Group and The Diabetes Incidence in Sweden Study (DISS) Group. Hormone and Metabolic Research.Hormon- Und Stoffwechselforschung. Hormones Et Metabolisme. 1996;28(7):344-347. Not sensitivity or specificity of an identified test. [pmid: 8858382].
Kocna P, Fric P, Tlaskalova H et al. Short-term cultivation of duodenal biopsies in patients with coeliac disease. Effect of gluten challenge and gliadin peptides. Advances in Experimental Medicine and Biology 1995;371b1367–1370. Not sensitivity or specificity of an identified test
Kocna Petr, Vanickova Zdislava, Perusicova Jindriska, et al. Tissue transglutaminase-serology markers for coeliac disease. Clinical Chemistry and Laboratory Medicine - Cclm / Fescc. 2002;40(5):485-492. Improper control group. [pmid: 12113293].
Koelle D M, Corey L, Burke R L, et al. Antigenic specificities of human CD4sup + T-cell clones recovered from recurrent genital herpes simplex virus type 2 lesions. J Virol. 1994;68(5):2803-2810. Not sensitivity or specificity of an identified test. [pmid: 7512152]. [pmcid: 236768].
Koelle D M, Johnson M L, Ekstrom A N, et al. Preferential presentation of herpes simplex virus T-cell antigen by HLA DQA1*0501/DQB1*0201 in comparison to HLA DQA1*0201/DQB1*0201. Human Immunology. 1997;53(2):195-205. Not sensitivity or specificity of an identified test. [pmid: 9129979].
Kohl D, Ashkenazi A, Ben Shaul Y, et al. Tight junctions of jejunal surface and crypt cells in celiac disease: a freeze-fracture study. Journal of Pediatric Gastroenterology and Nutrition. 1987;6(1):57-65. Not sensitivity or specificity of an identified test. [pmid: 3794934].
Koivisto V A, Kuitunen P, Tiilikainen A, et al. HLA antigens in patients with juvenile diabetes mellitus, coeliac disease and both of the diseases. Diabete & Metabolisme. 1977;3(1):49-53. Not sensitivity or specificity of an identified test. [pmid: 870355].
Koivisto V A, Kuitunen P, Tilikainen A, et al. HLA antigens, especially B8 and BW15, in patients with juvenile diabetes mellitus, coeliac disease, and both of these diseases [proceedings]. Diabete & Metabolisme. 1976;2(3):161. Not sensitivity or specificity of an identified test. [pmid: 1010138].
Kojecky Z, Matlocha Z, Pelikan L. Disaccharidase and LDH isoenzymes of intestnal mucosa. Clinical experiences in children and adults. Acta Univpalackiolomucfacmed. 1972;63(-):239-246. Not sensitivity or specificity of an identified test.
Kojima S, Inui T, Muramatsu H, et al. Dimerization of midkine by tissue transglutaminase and its functional implication. Journal of Biological Chemistry. 1997;272(14):9410-9416. Not sensitivity or specificity of an identified test. [pmid: 9083079].
Kojima S, Nara K, Rifkin D B. Requirement for transglutaminase in the activation of latent transforming growth factor-beta in bovine endothelial cells. J Cell Biol. 1993;121(2):439-448. Not sensitivity or specificity of an identified test. [pmid: 8096847].
Kokkonen J, Haapalahti M, Laurila K, et al. Cow's milk protein-sensitive enteropathy at school age. Journal of Pediatrics. 2001;139(6):797-803. Not sensitivity or specificity of an identified test. [pmid: 11743504].
Kokkonen J, Holm K, Karttunen T J, et al. Children with untreated food allergy express a relative increment in the density of duodenal gammadelta+ T cells. Scandinavian Journal of Gastroenterology. 2000;35(11):1137-1142. Not sensitivity or specificity of an identified test. [pmid: 11145283].
Kokkonen J, Simila S, Vuolukka P. The incidence of coeliac disease and pyloric stenosis in children in Northern Finland. Ann Clin Res. 1982;14(3):123-128. Not sensitivity or specificity of an identified test. [pmid: 7137881].
Kolacek S, Booth I W, Taylor C M. Food, mucosal immunity, and IgA nephropathy. Journal of Pediatric Gastroenterology and Nutrition. 1990;11(2):175-178. Not sensitivity or specificity of an identified test. [pmid: 2203890].
Kolek A, Fischerova E, Kos V et al. Application of ELISA method to determine antigliadin antibodies in children with coeliac disease. Acta Universitatis Palackianae Olomucensis Facultatis Medicae 1989;122183–192. Not sensitivity or specificity of an identified test
Kolek A, Vospe caron, Her caron, et al. Occurrence of coeliac disease in children with Down Syndrome in north Moravia, Czech Republic. European Journal of Pediatrics. 2003;162(3):207-208. Not sensitivity or specificity of an identified test. [pmid: 12655432].
Koletzko S, Burgin-Wolff A, Koletzko B, et al. Prevalence of coeliac disease in diabetic children and adolescents. A multicentre study. European Journal of Pediatrics. 1988;148(2):113-117. Not sensitivity or specificity of an identified test. [pmid: 3069470].
Kolho K L, Farkkila M A, Savilahti E. Undiagnosed coeliac disease is common in Finnish adults. Scandinavian Journal of Gastroenterology. 1998;33(12):1280-1283. Not sensitivity or specificity of an identified test. [pmid: 9930391].
Kolho K L, Tiitinen A, Tulppala M, et al. Screening for coeliac disease in women with a history of recurrent miscarriage or infertility. British Journal of Obstetrics and Gynaecology. 1999;106(2):171-173. Not sensitivity or specificity of an identified test. [pmid: 10426684].
Kolopp-Sarda M N, Massin N, Gobert B, et al. Humoral immune responses of workers occupationally exposed to wheat flour. Am J Ind Med. 1994;26(5):671-679. Not sensitivity or specificity of an identified test. [pmid: 7832214].
Kong Y-C, Flynn J C, Wan Q, et al. HLA and H2 class II transgenic mouse models to study susceptibility and protection in autoimmune thyroid disease. Autoimmunity. 2003;36(67):397-404. Not sensitivity or specificity of an identified test. [pmid: 14669947].
Koninckx C R, Giliams J P, Polanco I, et al. IgA antigliadin antibodies in celiac and inflammatory bowel disease. Journal of Pediatric Gastroenterology and Nutrition. 1984;3(5):676-682. Serology <1990. [pmid: 6502368].
Koning F. Celiac disease and malignancy: an immunological basis?. Journal of Pediatric Gastroenterology and Nutrition. 1997;24(5):S18-S19. Not sensitivity or specificity of an identified test. [pmid: 9161970].
Koning F. Immunotherapy of celiac disease: fact or fallacy?. Netherlands Journal of Medicine. 2002;60(7):305-306. Not sensitivity or specificity of an identified test. [pmid: 12430585].
Kontakou M, Przemioslo R T, Sturgess R P, et al. Expression of tumour necrosis factor-alpha, interleukin-6, and interleukin-2 mRNA in the jejunum of patients with coeliac disease. Scandinavian Journal of Gastroenterology. 1995;30(5):456-463. Not sensitivity or specificity of an identified test. [pmid: 7638572].
Kontakou M, Przemioslo R T, Sturgess R P, et al. Cytokine mRNA expression in the mucosa of treated coeliac patients after wheat peptide challenge. Gut. 1995;37(1):52-57. Not sensitivity or specificity of an identified test. [pmid: 7672681]. [pmcid: 1382768].
Kontakou M, Sturgess R P, Przemioslo R T, et al. Detection of interferon gamma mRNA in the mucosa of patients with coeliac disease by in situ hybridisation. Gut. 1994;35(8):1037-1041. Not sensitivity or specificity of an identified test. [pmid: 7926902]. [pmcid: 1375051].
Kontiainen S, Schlenzka A, Koskimies S, et al. Autoantibodies and autoimmune diseases in young diabetics. Diabetes Research (Edinburgh, Lothian). 1990;13(4):151-156. Not sensitivity or specificity of an identified test. [pmid: 2134205].
Koop I, Bozkurt T, Adler G, et al. Plasma cholecystokinin and pancreatic enzyme secretion in patients with coeliac sprue. Zeitschrift Fur Gastroenterologie. 1987;25(2):124-129. Not sensitivity or specificity of an identified test. [pmid: 2436388].
Koop I, Ilchmann R, Izzi L, et al. Detection of autoantibodies against tissue transglutaminase in patients with celiac disease and dermatitis herpetiformis. American Journal of Gastroenterology. 2000;95(8):2009-2014. Improper control group. [pmid: 10950050].
Koot V C, Van Straaten M, Hekkens W T, et al. Elevated level of IgA gliadin antibodies in patients with rheumatoid arthritis. Clinical and Experimental Rheumatology. 1989;7(6):623-626. Not sensitivity or specificity of an identified test. [pmid: 2612082].
Kordonouri O, Dieterich W, Schuppan D, et al. Autoantibodies to tissue transglutaminase are sensitive serological parameters for detecting silent coeliac disease in patients with Type 1 diabetes mellitus. Diabetic Medicine - a Journal of the British Diabetic Association. 2000;17(6):441-444. Improper control group. [pmid: 10975212].
Korhonen M, Ormio M, Burgeson R E, et al. Unaltered distribution of laminins, fibronectin, and tenascin in celiac intestinal mucosa. Journal of Histochemistry and Cytochemistry - Official Journal of the Histochemistry Society. 2000;48(7):1011-1020. Not sensitivity or specificity of an identified test.
Korponay-Szabo I R, Dahlbom I, Laurila K, et al. Elevation of IgG antibodies against tissue transglutaminase as a diagnostic tool for coeliac disease in selective IgA deficiency. Gut. 2003;52(11):1567-1571. Improper control group. [pmid: 14570724]. [pmcid: 1773847].
Korponay-Szabo I R, Kovacs J B, Czinner A, et al. High prevalence of silent celiac disease in preschool children screened with IgA/IgG antiendomysium antibodies. Journal of Pediatric Gastroenterology and Nutrition. 1999;28(1):26-30. Not sensitivity or specificity of an identified test. [pmid: 9890464].
Korponay-Szabo I R, Kovacs J B, Lorincz M, et al. Prospective significance of antiendomysium antibody positivity in subsequently verified celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1997;25(1):56-63. Improper control group. [pmid: 9226528].
Korponay-Szabo I R, Kovacs J B, Lorincz M, et al. The human appendix: A composite substrate for anti-endomysium, anti-reticulin and anti-bowel antibody testing in coeliac disease. Med Sci Monit. 1997;3(3):285-289. Not sensitivity or specificity of an identified test.
Korponay-Szabo I R, Laurila K, Szondy Z, et al. Missing endomysial and reticulin binding of coeliac antibodies in transglutaminase 2 knockout tissues. Gut. 2003;52(2):199-204. Not sensitivity or specificity of an identified test. [pmid: 12524400]. [pmcid: 1774982].
Korponay-Szabo I R, Sulkanen S, Halttunen T, et al. Tissue transglutaminase is the target in both rodent and primate tissues for celiac disease-specific autoantibodies. Journal of Pediatric Gastroenterology and Nutrition. 2000;31(5):520-527. Not sensitivity or specificity of an identified test. [pmid: 11144437].
Korponay-Szabo I, Kovacs J, Lorincz M, et al. Families with multiple cases of gluten-sensitive enteropathy. Zeitschrift Fur Gastroenterologie. 1998;36(7):553-558. Not sensitivity or specificity of an identified test. [pmid: 9738302].
Kortsik C S, Freudenberg N, Riede U, et al. Lectin binding sites and immunocytochemical characterization of normal pleural mesothelium. General & Diagnostic Pathology. 1995;141(2):141-146. Not sensitivity or specificity of an identified test. [pmid: 8548594].
Kosnai I, Kuitunen P, Savilahti E. Cell kinetics in the jejunal crypt epithelium in malabsorption syndrome with cow's milk protein intolerance and in coeliac disease of childhood. Gut. 1980;21(12):1041-1046. Not sensitivity or specificity of an identified test. [pmid: 7193162]. [pmcid: 1419399].
Kosnai I, Kuitunen P, Siimes M A. Iron deficiency in children with coeliac disease on treatment with gluten-free diet. Arch Dis Child. 1979;54(5):375-378. Not sensitivity or specificity of an identified test. [pmid: 314273].
Kosnai I, Kuitunen P, Savilahti E, et al. Mast cells and eosinophils in the jejunal mucosa of patients with intestinal cow's milk allergy and celiac disease of childhood. Journal of Pediatric Gastroenterology and Nutrition. 1984;3(3):368-372. Unable to extract data. [pmid: 6737181].
Koster-Kamphuis L, van Straaten E A, Kors W A, et al. Urinary NOx:creatinine ratios during gluten challenge in children with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 2003;36(3):372-375. Not sensitivity or specificity of an identified test. [pmid: 12604977].
Kotze Lorete, Maria da, Silva Utiyama, et al. IgA class anti-endomysial and anti-tissue transglutaminase antibodies in relation to duodenal mucosa changes in coeliac disease. Pathology. 2003;35(1):56-60. Improper control group. [pmid: 12701686].
Kotze L M, Utiyama S R, Nisihara R M, et al. Antiendomysium antibodies in Brazilian patients with celiac disease and their first-degree relatives. Arquivos De Gastroenterologia. 2001;38(2):94-103. Improper control group. [pmid: 11793949].
Kowalska E, Wasowska-Krolikowska K, Toporowska-Kowalska E. Estimation of antithyroid antibodies occurrence in children with coeliac disease. Medical Science Monitor - International Medical Journal of Experimental and Clinical Research. 2000;6(4):719-721. Not sensitivity or specificity of an identified test. [pmid: 11208398].
Krasilnikoff P A, Gudman-Hoyer E, Moltke H H. Diagnostic value of disaccharide tolerance tests in children. Acta Paediatrica Scandinavica. 1975;64(5):693-698. Not sensitivity or specificity of an identified test. [pmid: 1166789].
Kraut J R, Lloyd-Still J D. The 1-hr blood xylose test in the evaluation of malabsorption in infants and children. American Journal of Clinical Nutrition. 1980;33(11):2328-2333. Not sensitivity or specificity of an identified test. [pmid: 7435413].
Krawitt E L, Beeken W L. Limitations of the usefulness of the d-xylose absorption test. American Journal of Clinical Pathology. 1975;63(2):261-263. Not sensitivity or specificity of an identified test. [pmid: 46695].
Krig S R, Rice R H. TCDD suppression of tissue transglutaminase stimulation by retinoids in malignant human keratinocytes. Toxicol Sci. 2000;56(2):357-364. Not sensitivity or specificity of an identified test. [pmid: 10910994].
Krig S R, Chandraratna R A S, Chang M M J, et al. Gene-specific TCDD suppression of RARalpha- and RXR-mediated induction of tissue transglutaminase. Toxicol Sci. 2002;68(1):102-108. Not sensitivity or specificity of an identified test. [pmid: 12075115].
Krilis S A, Macpherson J L, de Carle D J, et al. Small bowel mucosa from celiac patients generates 15-hydroxyeicosatetraenoic acid (15-HETE) after in vitro challenge with gluten. Journal of Immunology (Baltimore, Md- 1950). 1986;137(12):3768-3771. Not sensitivity or specificity of an identified test. [pmid: 3097132].
Krupickova S, Tuckova L, Flegelova Z, et al. Identification of common epitopes on gliadin, enterocytes, and calreticulin recognised by antigliadin antibodies of patients with coeliac disease. Gut. 1999;44(2):168-173. Not sensitivity or specificity of an identified test. [pmid: 9895374]. [pmcid: 1727378].
Kubilus J, Baden H P. Isolation of two immunologically related transglutaminase substrates from cultured human keratinocytes. In Vitro. 1982;18(5):447-455. Not sensitivity or specificity of an identified test. [pmid: 6180968].
Kubilus J, Kvedar J, Baden H P. Identification of new components of the cornified envelope of human and bovine epidermis. Journal of Investigative Dermatology. 1987;89(1):44-50. Not sensitivity or specificity of an identified test. [pmid: 3298447].
Kucera P, Novakova D, Behanova M, et al. Gliadin, endomysial and thyroid antibodies in patients with latent autoimmune diabetes of adults (LADA). Clinical and Experimental Immunology. 2003;133(1):139-143. Not sensitivity or specificity of an identified test. [pmid: 12823288]. [pmcid: 1808742].
Kudo S. Role of sperm head syndecan at fertilization in fish. Journal of Experimental Zoology. 1998;281(6):620-625. Not sensitivity or specificity of an identified test. [pmid: 9697326].
Kuitunen M, Savilahti E. Gut permeability to human alpha-lactalbumin, beta-lactoglobulin, mannitol, and lactulose in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1996;22(2):197-204. Not sensitivity or specificity of an identified test. [pmid: 8642494].
Kuitunen Mikael, Saukkonen Tero, Ilonen Jorma, et al. Intestinal permeability to mannitol and lactulose in children with type 1 diabetes with the HLA-DQB1*02 allele. Autoimmunity. 2002;35(5):365-368. Not sensitivity or specificity of an identified test. [pmid: 12515291].
Kuitunen P, Kosnai I, Savilahti E. Morphometric study of the jejunal mucosa in various childhood enteropathies with special reference to intraepithelial lymphocytes. Journal of Pediatric Gastroenterology and Nutrition. 1982;1(4):525-531. Unable to extract data. [pmid: 7186067].
Kuitunen P, Visakorpi J K, Savilahti E, et al. Malabsorption syndrome with cow's milk intolerance Clinical findings and course in 54 cases. Archives of Disease in Childhood. 1975;50(5):351-356. Not sensitivity or specificity of an identified test. [pmid: 1242623].
Kuks J B M, Lems S P M, Oosterhuis H J G H. HLA type is not indicative for the effect of thymectomy in myasthenia gravis. J Neuroimmunol. 1992;36(23):217-224. Not sensitivity or specificity of an identified test. [pmid: 1732282].
Kull K, Uibo O, Salupere R, et al. High frequency of antigliadin antibodies and absence of antireticulin and antiendomysium antibodies in patients with ulcerative colitis. Journal of Gastroenterology. 1999;34(1):61-65. Not sensitivity or specificity of an identified test. [pmid: 10204612].
Kumar P, Bartram C I. Relevance of the barium follow-through examination in the diagnosis of adult celiac disease. Gastrointestinal Radiology. 1979;4(3):285-289. Not sensitivity or specificity of an identified test. [pmid: 556235].
Kumar P, Clark M. Primary biliary cirrhosis and coeliac disease. Is there an association?. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(4):248-250. Not sensitivity or specificity of an identified test. [pmid: 12038807].
Kumar P J. European and North American populations should be screened for coeliac disease. Gut. 2003;52(2):170-171. Not sensitivity or specificity of an identified test. [pmid: 12692052]. [pmcid: 1774950].
Kumar P J. Clinial pathology of celiac disease. Curr Opin Gastroenterol. 1991;7(2):232-235. Review article.
Kumar P J, Ferguson A, Lancaster-Smith M, et al. Food antibodies in patients with dermatitis herpetiformis and adult coeliac disease - relationship to jejunal morphology. Scandinavian Journal of Gastroenterology. 1976;11(1):5-9. Not sensitivity or specificity of an identified test. [pmid: 946332].
Kumar P J, O'Donoghue D P, Stenson K, et al. Reintroduction of gluten in adults and children with treated coeliac disease. Gut. 1979;20(9):743-749. Not sensitivity or specificity of an identified test. [pmid: 499912]. [pmcid: 1412650].
Kumar P J, Silk D B A, Marks R. Functional and morphological changes in response to a gluten free diet and corticosteroids in dermatitis herpetiformis and adult coeliac disease. Br J Dermatol. 1973;89(Suppl 9):13. Not sensitivity or specificity of an identified test.
Kumar P J, Silk D B, Rousseau B, et al. Assessment of jejunal function in patients with dermatitis herpetiformis and adult coeliac disease using a perfusion technique. Scandinavian Journal of Gastroenterology. 1974;9(8):793-798. Not sensitivity or specificity of an identified test. [pmid: 4432052].
Kumar P J, Walker-Smith J, Milla P, et al. The teenage coeliac: Follow up study of 102 patients. Arch Dis Child. 1988;63(8):916-920. Not sensitivity or specificity of an identified test. [pmid: 3415327].
Kumar R, Lumsden A, Ciclitira P J, et al. Human genome search in celiac disease using gliadin cDNA as probe. J Mol Biol. 2000;300(5):1155-1167. Not sensitivity or specificity of an identified test. [pmid: 10903861].
Kumar Rajesh, Eastwood Amy L, Brown Milton L, et al. Human genome search in celiac disease: mutated gliadin T-cell-like epitope in two human proteins promotest T-cell activation. Journal of Molecular Biology. 2002;319(3):593-602. Not sensitivity or specificity of an identified test. [pmid: 12054857].
Kumar V, Beutner E H, Chorzelski T P. Antiendomysial antibody--useful serological indicator of dermatitis herpetiformis. Archives of Dermatological Research. 1987;279(7):454-458. Not sensitivity or specificity of an identified test. [pmid: 3435174].
Kumar V, Beutner E H, Chorzelski T P. Distribution of monkey esophagus antigens reactive with IgA-class antibodies in the sera of dermatitis herpetiformis patients. Archives of Dermatological Research. 1984;276(5):293-296. Not sensitivity or specificity of an identified test. [pmid: 6385871].
Kumar V, Hemedinger E, Chorzelski T P, et al. Reticulin and endomysial antibodies in bullous diseases. Comparison of specificity and sensitivity. Archives of Dermatology. 1987;123(9):1179-1182. Not sensitivity or specificity of an identified test. [pmid: 3307639].
Kumar V, Jain N, Beutner E H, et al. Detection of antigliadin antibodies in bullous diseases and their recognition of similar antigenic polypeptides. International Archives of Allergy and Applied Immunology. 1987;83(2):155-159. Not sensitivity or specificity of an identified test. [pmid: 3294600].
Kumar V, Jain N, Lerner A, et al. Comparative studies of different gliadin preparations in detecting antigliadin antibodies. Journal of Pediatric Gastroenterology and Nutrition. 1986;5(5):730-734. Not sensitivity or specificity of an identified test. [pmid: 3531457].
Kumar V, Jarzabek-Chorzelska M, Sulej J, et al. Celiac disease and immunoglobulin a deficiency: how effective are the serological methods of diagnosis?. Clinical and Diagnostic Laboratory Immunology. 2002;9(6):1295-1300. Improper control group. [pmid: 12414763]. [pmcid: 130112].
Kumar V, Jarzabek-Chorzelska M, Sulej J, et al. Tissue transglutaminase and endomysial antibodies-diagnostic markers of gluten-sensitive enteropathy in dermatitis herpetiformis. Clinical Immunology (Orlando, Fla). 2001;98(3):378-382. Not sensitivity or specificity of an identified test. [pmid: 11237562].
Kumar V, Rajadhyaksha M, Wortsman J. Celiac disease-associated autoimmune endocrinopathies. Clinical and Diagnostic Laboratory Immunology. 2001;8(4):678-685. Not sensitivity or specificity of an identified test. [pmid: 11427410]. [pmcid: 96126].
Kumar V, Zane H, Kaul N. Serologic markers of gluten-sensitive enteropathy in bullous diseases. Archives of Dermatology. 1992;128(11):1474-1478. Not sensitivity or specificity of an identified test. [pmid: 1444501].
Kuncio G S, Tsyganskaya M, Zhu J, et al. TNF-alpha modulates expression of the tissue transglutaminase gene in liver cells. American Journal of Physiology. 1998;274(2 Pt 1):G240-G245. Not sensitivity or specificity of an identified test. [pmid: 9486175].
Kundakc cedil, Oskay T, Olmez U, et al. Association of psoriasis vulgaris with HLA class I and class II antigens in the Turkish population, according to the age at onset. Int J Dermatol. 2002;41(6):345-348. Not sensitivity or specificity of an identified test. [pmid: 12100689].
Kurki P, Heliovaara M, Palosou T, et al. Food intolerance and rheumatoid arthritis. Lancet. 1988;2(8625):1419-1420. Not sensitivity or specificity of an identified test. [pmid: 2904540].
Kuscu N K, Akcali S, Kucukmetin N T. Celiac disease and polycystic ovary syndrome. Int J Gynecol Obstet. 2002;79(2):149-150. Not sensitivity or specificity of an identified test.
Kutlu T, Brousse N, Rambaud C, et al. Numbers of T cell receptor (TCR) alpha beta+ but not of TcR gamma delta+ intraepithelial lymphocytes correlate with the grade of villous atrophy in coeliac patients on a long term normal diet. Gut. 1993;34(2):208-214. Improper control group. [pmid: 8432475]. [pmcid: 1373972].
Kvedar J C, Manabe M, Phillips S B et al. Characterization of sciellin, a precursor to the cornified envelope of human keratinocytes. Differentiation 1992;Research in Biological Diversity; 49(3):195–204. Not sensitivity or specificity of an identified test
Kvedar J C, Pion I A, Bilodeau E B, et al. Detection of substratest of keratinocyte transglutaminase in vitro and in vivo using a monoclonal antibody to dansylcadaverine. Biochemistry. 1992;31(1):49-56. Not sensitivity or specificity of an identified test. [pmid: 1370626].
Kwok W W, Nepom G T, Raymond F C. HLA-DQ polymorphisms are highly selective for peptide binding interactions. Journal of Immunology (Baltimore, Md - 1950). 1995;155(5):2468-2476. Not sensitivity or specificity of an identified test. [pmid: 7650377].
Kwok W W, Schwarz D, Nepom B S, et al. HLA-DQ molecules from alpha-beta heterodimers of mixed allotype. J Immunol. 1988;141(9):3123-3127. Not sensitivity or specificity of an identified test. [pmid: 2844907].
Kwok W W, Thurtle P, Nepom G T. A genetically controlled pairing anomaly between HLA-DQalpha and HLA-DQbeta chains. J Immunol. 1989;143(11):3598-3601. Not sensitivity or specificity of an identified test. [pmid: 2479684].
L'Hirondel C, Doe W F, Peters T J. Biochemical and morphological studies on human jejunal mucosa maintained in culture. Clinical Science and Molecular Medicine. 1976;50(5):425-429. Not sensitivity or specificity of an identified test. [pmid: 1277750].
L'Hirondel C, Doe W F, Peters T J. Proceedings: Use of an improved jejunal culture system for the study of normal and coeliac mucosa. Gut. 1975;16(5):392. Not sensitivity or specificity of an identified test. [pmid: 1140637]. [pmcid: 1411065].
La Seta F, Salerno G, Buccellato A, et al. Radiographic indicants of adult celiac disease assessed by double-contrast small bowel enteroclysis. European Journal of Radiology. 1992;15(2):157-162. Not sensitivity or specificity of an identified test. [pmid: 1425755].
Labate A, Gambardella A, Messina D, et al. Silent celiac disease in patients with childhood localization-related epilepsies. Epilepsia. 2001;42(9):1153-1155. Not sensitivity or specificity of an identified test. [pmid: 11580763].
Labo G, Gasbarrini G, Migli F, et al. Thelio-and propriolymphocytes count in normal subjects and in primary and secondary enteropathy. G.e.n. 1978;32(4):403-417. Not sensitivity or specificity of an identified test. [pmid: 113282].
LaCelle P T, Lambert A, Ekambaram M C, et al. In vitro cross-linking of recombinant human involucrin. Skin Pharmacology and Applied Skin Physiology. 1998;11(45):214-226. Not sensitivity or specificity of an identified test. [pmid: 9885405].
Lagerqvist C, Ivarsson A, Juto P, et al. Screening for adult coeliac disease - which serological marker(s) to use?. Journal of Internal Medicine. 2001;250(3):241-248. Improper control group. [pmid: 11555129].
Lagrange M, Ferrero J M, Lagrange J L, et al. Non-specifically labelled cells that simulate bone marrow metastases in patients with non-metastatic breast cancer. Journal of Clinical Pathology. 1997;50(3):206-211. Not sensitivity or specificity of an identified test. [pmid: 9155670]. [pmcid: 499814].
Lahat E, Broide E, Leshem M, et al. Prevalence of celiac antibodies in children with neurologic disorders. Pediatr Neurol. 2000;22(5):393-396. Not sensitivity or specificity of an identified test. [pmid: 10913732].
Lahat N, Be-Nun A, Cohen L, et al. T cell receptor repertoire in the peripheral blood and intestinal mucosa of coeliac patients. Clinical and Experimental Immunology. 1995;101(3):422-427. Not sensitivity or specificity of an identified test. [pmid: 7664488]. [pmcid: 1553235].
Lahdeaho M L, Lehtinen M, Rissa H R, et al. Antipeptide antibodies to adenovirus E1b protein indicate enhanced risk of celiac disease and dermatitis herpetiformis. International Archives of Allergy and Immunology. 1993;101(3):272-276. Not sensitivity or specificity of an identified test. [pmid: 8324388].
Lahteenoja H, Maki M, Viander M, et al. Local challenge of oral mucosa with gliadin in patients with coeliac disease. Clinical and Experimental Immunology. 2000;120(1):38-45. Not sensitivity or specificity of an identified test. [pmid: 10759761]. [pmcid: 1905618].
Lahteenoja H, Toivanen A, Raiha I, et al. Salivary antigliadin and antiendomysium antibodies in coeliac disease. Scandinavian Journal of Immunology. 1999;50(5):528-535. Not sensitivity or specificity of an identified test. [pmid: 10564556].
Lahteenoja H, Toivanen A, Viander M, et al. Oral mucosal changes in coeliac patients on a gluten-free diet. European Journal of Oral Sciences. 1998;106(5):899-906. Not sensitivity or specificity of an identified test. [pmid: 9786318].
Lahteenoja H, Toivanen A, Viander M, et al. Increase in T-cell subsets of oral mucosa: a late immune response in patients with treated coeliac disease?. Scandinavian Journal of Immunology. 2000;52(6):602-608. Not sensitivity or specificity of an identified test. [pmid: 11119267].
Lai T S, Bielawska A, Peoples K A, et al. Sphingosylphosphocholine reduces the calcium ion requirement for activating tissue transglutaminase. Journal of Biological Chemistry. 1997;272(26):16295-16300. Not sensitivity or specificity of an identified test. [pmid: 9195933].
Lai T S, Hausladen A, Slaughter T F, et al. Calcium regulatest S-nitrosylation, denitrosylation, and activity of tissue transglutaminase. Biochemistry. 2001;40(16):4904-4910. Not sensitivity or specificity of an identified test. [pmid: 11305905].
Lai T S, Slaughter T F, Koropchak C M, et al. C-terminal deletion of human tissue transglutaminase enhances magnesium-dependent GTP/ATPase activity. Journal of Biological Chemistry. 1996;271(49):31191-31195. Not sensitivity or specificity of an identified test. [pmid: 8940119].
Lai T S, Slaughter T F, Peoples K A, et al. Regulation of human tissue transglutaminase function by magnesium-nucleotide complexes. Identification of distinct binding sites for Mg-GTP and Mg-ATP. Journal of Biological Chemistry. 1998;273(3):1776-1781. Not sensitivity or specificity of an identified test. [pmid: 9430726].
Lamabadusuriya S P, Packer S, Harries J T. Limitations of xylose tolerance test as a screening procedure in childhood coeliac disease. Archives of Disease in Childhood. 1975;50(1):34-39. Not sensitivity or specificity of an identified test. [pmid: 1124941].
Lamabadusuriya S P, Packer S, Harries J T. Proceedings: Limitations of xylose tolerance test as screening procedure for coeliac disease. Archives of Disease in Childhood. 1974;49(3):244-245. Not sensitivity or specificity of an identified test. [pmid: 4825637].
Lampasona V, Bazzigaluppi E, Barera G, et al. Tissue transglutaminase and combined screening for coeliac disease and type 1 diabetes-associated autoantibodies. Lancet. 1998;352(9135):1192-1193. Not sensitivity or specificity of an identified test. [pmid: 9777840].
Lampasona V, Bonfanti R, Bazzigaluppi E, et al. Antibodies to tissue transglutaminase C in type I diabetes. Diabetologia. 1999;42(10):1195-1198. Not sensitivity or specificity of an identified test. [pmid: 10525659].
Lancaster Smith M, Kumar P, Marks R. Immunofluorescence of the jejunal mucosa in dermatitis herpetiformis and adult coeliac disease. Br J Dermatol. 1973;89(Suppl 9):13-14. Not sensitivity or specificity of an identified test.
Lancaster-Smith M, Joyce S, Kumar P. Immunoglobulins in the jejunal mucosa in adult coeliac disease and dermatitis herpetiformis after the reintroduction of dietary gluten. Gut. 1977;18(11):887-891. Not sensitivity or specificity of an identified test. [pmid: 338443]. [pmcid: 1411725].
Lancaster-Smith M, Kumar P, Clark M L, et al. Antireticulin antibodies in dermatitis herpetiformis and adult coeliac disease. Their relationship to a gluten free diet and jejunal histology. British Journal of Dermatology. 1975;92(1):37-42. Not sensitivity or specificity of an identified test. [pmid: 1156543].
Lancaster-Smith M, Packer S, Kumar P J, et al. Immunological phenomena in the jejunum and serum after reintroduction of dietary gluten in children with treated coeliac disease. Journal of Clinical Pathology. 1976;29(7):592-597. Not sensitivity or specificity of an identified test. [pmid: 977769]. [pmcid: 476123].
Landini M P, Lazzarotto T, La Placa M. The immune response to human cytomegalovirus-induced early nuclear and early membrane antigens and its possible clinical significance. Journal of Infection. 1984;9(3):257-263. Not sensitivity or specificity of an identified test. [pmid: 6098617].
Lang C C, Brown R M, Kinirons M T, et al. Decreased intestal CYP3A in celiac disease: reversal after successful gluten-free diet: a potential source of interindividual variability in first-pass drug metabolism. Clinical Pharmacology and Therapeutics. 1996;59(1):41-46. Not sensitivity or specificity of an identified test. [pmid: 8549032].
Langman M J, Banwell J G, Stewart J S, et al. ABO blood groups, secretor status, and intestinal alkaline phosphatase concentrations in patients with celiac disease. Gastroenterology. 1969;57(1):19-23. Not sensitivity or specificity of an identified test. [pmid: 5788646].
Lankisch P G, Martinez Schramm A, Petersen F, et al. Diagnostic intervals for recognizing celiac disease. Zeitschrift Fur Gastroenterologie. 1996;34(8):473-477. Not sensitivity or specificity of an identified test. [pmid: 8794542].
Lanspa S J, Chan A T, Bell J S, et al. Pathogenesis of steatorrhea in primary biliary cirrhosis. Hepatology (Baltimore, Md). 1985;5(5):837-842. Not sensitivity or specificity of an identified test. [pmid: 2411648].
Lape M L, Baker J A, Chan J K. A comparison of immunofluorescent assays to detect anti-granulocyte antibodies. American Journal of Clinical Pathology. 1985;84(4):464-468. Not sensitivity or specificity of an identified test. [pmid: 3898809].
Lapini M, Lasagni D, Ferrari R. Detection of anti-smooth muscle antibodies in the sera of patients with celiac disease: Relationship with anti-endomysium antibodies. Eur J Lab Med. 1998;6(3):174-176. Not sensitivity or specificity of an identified test.
Lardy N M, Bakas R M, Van der, et al. CIS-acting regulatory elements abrogate allele-specific HLA class I gene expression in healthy individuals. J Immunol. 1992;148(8):2572-2577. Not sensitivity or specificity of an identified test. [pmid: 1560211].
Larizza D, Calcaterra V, De Giacomo C, et al. Celiac disease in children with autoimmune thyroid disease. Journal of Pediatrics. 2001;139(5):738-740. Not sensitivity or specificity of an identified test. [pmid: 11713456].
Larizza D, Calcaterra V, Luinetti O, et al. Evidence for immunogenetic predisposition in children with celiac disease and autoimmune thyroid disease. Int J Med Biol Environ. 2001;29(2):143-148. Not sensitivity or specificity of an identified test.
Larizza D, Martinetti M, Lorini R, et al. Parental segregation of autoimmunity in patients with Turner's syndrome: Preferential paternal transmission?. J Autoimmun. 1999;12(1):65-72. Not sensitivity or specificity of an identified test. [pmid: 10028024].
Lasagni D, Ferrari R, Lapini M. Unmasking anti-endomysial antibodies in coeliac subjects positive for anti-smooth muscle antibodies. Acta Paediatrica (Oslo, Norway - 1992). 1999;88(4):462-464. Not sensitivity or specificity of an identified test. [pmid: 10342549].
Latham S, Becket A J, Chapell D A. Further modifications in the children's jejunal biopsy capsule. British Medical Journal. 1969;2(651):243. Not sensitivity or specificity of an identified test. [pmid: 5780436]. [pmcid: 1983102].
Laurent J, Branellec A, Heslan J M, et al. An increase in circulating IgA antibodies to gliadin in IgA mesangial glomerulonephritis. American Journal of Nephrology. 1987;7(3):178-183. Not sensitivity or specificity of an identified test. [pmid: 3631148].
Laurie G W, Ciclitira P J, Ellis H J, et al. Immunological and partial sequence identity of mouse BM180 with wheat alpha-gliadin. Biochemical and Biophysical Research Communications. 1995;217(1):10-15. Not sensitivity or specificity of an identified test. [pmid: 8526896].
Laurin P, Falth-Magnusson K, Sundqvist T. Increase in nitric oxide urinary products during gluten challenge in children with coeliac disease. Scandinavian Journal of Gastroenterology. 2003;38(1):55-60. Not sensitivity or specificity of an identified test. [pmid: 12608465].
Laurin Pia, Wolving Mats, Falth-Magnusson Karin. Even small amounts of gluten cause relapse in children with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 2002;34(1):26-30. Not sensitivity or specificity of an identified test. [pmid: 11753160].
Lauritsen K B, Lauritzen J B, Christensen K C. Gastric inhibitory polypeptide and insulin release in response to oral and intravenous glucose in coeliac disease. Scandinavian Journal of Gastroenterology. 1982;17(2):241-245. Not sensitivity or specificity of an identified test. [pmid: 6753103].
Lauritzen A F. Distinction between cells in serous effusions using a panel of antibodies. Virchows Archiv. A, Pathological Anatomy and Histopathology. 1987;411(3):299-304. Not sensitivity or specificity of an identified test.
Lavo B, Knutson F, Knutson L, et al. Jejunal secretion of secretory immunoglobulins and gliadin antibodies in celiac disease. Digestive Diseases and Sciences. 1992;37(1):53-59. Not sensitivity or specificity of an identified test. [pmid: 1728531].
Lavo B, Knutson L, Loof L, et al. Signs of increased leakage over the jejunal mucosa during gliadin challenge of patients with coeliac disease. Gut. 1990;31(2):153-157. Not sensitivity or specificity of an identified test. [pmid: 2179068]. [pmcid: 1378371].
Lawler M, Humphries P, O'Farrelly C, et al. Adenovirus 12 E1A gene detection by polymerase chain reaction in both the normal and coeliac duodenum. Gut. 1994;35(9):1226-1232. Not sensitivity or specificity of an identified test. [pmid: 7959228]. [pmcid: 1375698].
Lazzari R, Volta U, Bianchi F B, et al. R1 reticulin antibodies: markers of celiac disease in children on a normal diet and on gluten challenge. Journal of Pediatric Gastroenterology and Nutrition. 1984;3(4):516-522. Not sensitivity or specificity of an identified test. [pmid: 6384456].
Le Quellec A, Clapie M, Callamand P, et al. Circulating oxyntomodulin-like immunoreactivity in healthy children and children with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1998;27(5):513-518. Not sensitivity or specificity of an identified test. [pmid: 9822314].
Le Tourneau A, Audouin J, Diebold J. Ultrastructural study of 4 cases of Ki-1 positive large anaplastic cell malignant lymphoma. Virchows Archiv. A, Pathological Anatomy and Histopathology. 1988;413(3):215-222. Not sensitivity or specificity of an identified test.
Lebenthal E, Branski D. Childhood celiac disease--a reappraisal. Journal of Pediatrics. 1981;98(5):681-690. Not sensitivity or specificity of an identified test. [pmid: 7229747].
Lebenthal E, Heitlinger L A. Gliadin antibodies in celiac disease. Journal of Pediatrics. 1983;102(5):711-712. Not sensitivity or specificity of an identified test. [pmid: 6842326].
Lebenthal E, Antonowicz I, Shwachman H. The interrelationship of enterokinase and trypsin activities in intractable diarrhea of infancy, celiac disease, and intravenous alimentation. Pediatrics. 1975;56(4):585-591. Not sensitivity or specificity of an identified test. [pmid: 809741].
Lebenthal Emanuel, Branski David. Serum anti-endomysial and anti-tissue transglutaminase for screening of celiac disease. Israel Medical Association Journal - Imaj. 2002;4(8):627-628. Not sensitivity or specificity of an identified test.
Lee C H, Lee S K, Chi J G, et al. Immunohistochemical evaluation of transglutaminase C in tumours of salivary glands European Journal of Cancer. Part B, Oral Oncology. 1996;32b(6):401-406. Not sensitivity or specificity of an identified test.
Lee F I, Prior J, Murray S M. Celiac disease in monozygous twin boys Asynchronous presentation. Digestive Diseases and Sciences. 1982;27(12):1137-1140. Not sensitivity or specificity of an identified test. [pmid: 6890892].
Lee J H, Jang S I, Yang J M, et al. The proximal promoter of the human transglutaminase 3 gene. Stratified squamous epithelial-specific expression in cultured cells is mediated by binding of Sp1 and ets transcription factors to a proximal promoter element. Journal of Biological Chemistry. 1996;271(8):4561-4568. Not sensitivity or specificity of an identified test. [pmid: 8626812].
Lee K H, Wucherpfennig K W, Wiley D C. Structure of a human insulin peptide-HLA-DQ8 complex and susceptibility to type 1 diabetes. Nature Immunology. 2001;2(6):501-507. Not sensitivity or specificity of an identified test. [pmid: 11376336].
Lee K N, Arnold S A, Birckbichler P J, et al. Site-directed mutagenesis of human tissue transglutaminase: Cys-277 is essential for transglutaminase activity but not for GTPase activity. Biochimica Et Biophysica Acta. 1993;1202(1):1-6. Not sensitivity or specificity of an identified test. [pmid: 8104036].
Lee K N, Birckbichler P J, Fesus L. Purification of human erythrocyte transglutaminase by immunoaffinity chromatography. Preparative Biochemistry. 1986;16(4):321-335. Not sensitivity or specificity of an identified test. [pmid: 2880343].
Lee K N, Birckbichler P J, Patterson M K, et al. Induction of cellular transglutaminase biosynthesis by sodium butyrate. Biochimica Et Biophysica Acta. 1987;928(1):22-28. Not sensitivity or specificity of an identified test. [pmid: 2881581].
Lee K N, Lee C S, Tae W-C, et al. Cross-linking of wild-type and mutant alphaSUB2-antiplasmins to by activated factor XIII and by a tissue transglutaminase. J Biol Chem. 2000;275(48):37382-37389. Not sensitivity or specificity of an identified test. [pmid: 10958788].
Lee S K, Chi J G, Jeon Y J, et al. Expression of transglutaminase C during the prenatal development of human submandibular glands. Journal of Dental Research. 1995;74(11):1812-1816. Not sensitivity or specificity of an identified test. [pmid: 8530745].
Lee S K, Chi J G, Park S C, et al. Transient expression of transglutaminase C during prenatal development of human muscles. Journal of Histochemistry and Cytochemistry - Official Journal of the Histochemistry Society. 2000;48(11):1565-1574. Not sensitivity or specificity of an identified test.
Lee Susie K, Lo Winson, Memeo Lorenzo, et al. Duodenal histology in patients with celiac disease after treatment with a gluten-free diet. Gastrointestinal Endoscopy. 2003;57(2):187-191. Not sensitivity or specificity of an identified test. [pmid: 12556782].
Lee Y-S, Dlugosz A A, McKay R, et al. Definition by specific antisense oligonucleotides of a role for protein kinase Calpha in expression of differentiation markers in normal and neoplastic mouse epidermal keratinocytes. Mol Carcinog. 1997;18(1):44-53. Not sensitivity or specificity of an identified test. [pmid: 9022812].
Lefebvre O, Wouters D, Mereau-Richard C, et al. Induction of apoptosis by all-trans retinoic acid in the human myeloma cell line RPMI 8226 and negative regulation of some of its typical morphological features by dexamethasone. Cell Death and Differentiation. 1999;6(5):433-444. Not sensitivity or specificity of an identified test. [pmid: 10381637].
Leffell M S. Is there an immunogenetic basis for Peyronie's disease?. J Urol. 1997;157(1):295-297. Not sensitivity or specificity of an identified test. [pmid: 8976283].
Lehmann F G, Hillert U. Fecal intestinal alkaline phosphatase in coeliac disease. Zeitschrift Fur Gastroenterologie. 1980;18(7):381-388. Not sensitivity or specificity of an identified test. [pmid: 7424078].
Leigh R J, Marsh M N, Crowe P, et al. Studies of intestinal lymphoid tissue. IX. Dose-dependent, gluten-induced lymphoid infiltration of coeliac jejunal epithelium. Scandinavian Journal of Gastroenterology. 1985;20(6):715-719. Not sensitivity or specificity of an identified test. [pmid: 4035290].
Lembcke B, Schneider H, Lankisch P G. Is the assay of disaccharidase activity in small bowel mucosal biopsy relevant for clinical gastroenterologists?. Klinische Wochenschrift. 1989;67(11):568-575. Not sensitivity or specificity of an identified test. [pmid: 2747134].
Lemieux B, Boivin M, Brossard J-H, et al. Normal parathyroid function with decreased bone mineral density in treated celiac disease. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 2001;15(5):302-307. Not sensitivity or specificity of an identified test. [pmid: 11381297].
Lenoir-Viale M C, Galup C, Darmon M, et al. Epidermis reconstructed from the outer root sheath of human hair follicle. Effect of retinoic acid. Archives of Dermatological Research. 1993;285(4):197-204. Not sensitivity or specificity of an identified test. [pmid: 8342963].
Lentze M, Schaub J, Harms K. A simple thin-layer chromatographic technique for the assay of intestinal dipeptide hydrolases from human mucosal biopsy material. Clinica Chimica Acta 1973;International Journal of Clinical Chemistry; 49(1):19–26. Not sensitivity or specificity of an identified test
Leon F, Camarero C, Pena R, et al. Anti-transglutaminase IgA ELISA: clinical potential and drawbacks in celiac disease diagnosis. Scandinavian Journal of Gastroenterology. 2001;36(8):849-853. Improper control group. [pmid: 11495081].
Leonard J N, Chorzelski T P, Beutner E H, et al. IgA anti-endomysial antibody detection in the serum of patients with dermatitis herpetiformis following gluten challenge. Archives of Dermatological Research. 1985;277(5):349-351. Not sensitivity or specificity of an identified test. [pmid: 4026376].
Leonard J N, Tucker W F, Fry J S, et al. Increased incidence of malignancy in dermatitis herpetiformis. British Medical Journal (Clinical Research Ed). 1983;286(6358):16-18. Not sensitivity or specificity of an identified test. [pmid: 6401441]. [pmcid: 1546663].
Leonard J, Haffenden G, Tucker W. Gluten challenge in dermatitis herpetiformis. New Engl J Med. 1983;308(14):816-819. Not sensitivity or specificity of an identified test. [pmid: 6339917].
Leonard N, Feighery C F, Hourihane D O, et al. Peptic duodenitis - Does it exist in the second part of the duodenum?. J Clin Pathol. 1997;50(1):54-58. Not sensitivity or specificity of an identified test. [pmid: 9059358]. [pmcid: 499714].
Leonard N, Hourihane D O, Whelan A. Neuroproliferation in the mucosa is a feature of coeliac disease and Crohn's disease. Gut. 1995;37(6):763-765. Not sensitivity or specificity of an identified test. [pmid: 8537045]. [pmcid: 1382936].
Leong A S, Sormunen R T, Tsui W M, et al. Hep Par 1 and selected antibodies in the immunohistological distinction of hepatocellular carcinoma from cholangiocarcinoma, combined tumours and metastatic carcinoma. Histopathology. 1998;33(4):318-324. Not sensitivity or specificity of an identified test. [pmid: 9822920].
Lepage V, Lamm L U, Charron D. Molecular aspects of HLA class II and some autoimmune diseases. Eur J Immunogenet. 1993;20(3):153-164. Not sensitivity or specificity of an identified test. [pmid: 8338813].
Lepore L, Martelossi S, Pennesi M, et al. Prevalence of celiac disease in patients with juvenile chronic arthritis. Journal of Pediatrics. 1996;129(2):311-313. Not sensitivity or specificity of an identified test. [pmid: 8765635].
Lepore L, Pennesi M, Ventura A, et al. Anti-alpha-gliadin antibodies are not predictive of celiac disease in juvenile chronic arthritis. Acta Paediatrica (Oslo, Norway - 1992). 1993;82(67):569-573. Not sensitivity or specificity of an identified test. [pmid: 8338992].
Lerner A. The race for the diagnostic autoantibody in celiac disease. And the winner is…. Israel Medical Association Journal - Imaj. 2000;2(2):82-83. Not sensitivity or specificity of an identified test.
Lerner A. Factors affecting the clinical presentation and time of diagnosis of celiac disease: the Jerusalem and the West Bank-Gaza experience. Israel Journal of Medical Sciences. 1994;30(4):294-295. Not sensitivity or specificity of an identified test. [pmid: 8050879].
Lerner A, Lebenthal E. The controversy of the use of anti-gluten antibody (AGA) as a diagnostic tool in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1991;12(4):407-409. Not sensitivity or specificity of an identified test. [pmid: 1941417].
Lerner A, Blank M, Lahat N, et al. Increased prevalence of autoantibodies in celiac disease. Digestive Diseases and Sciences. 1998;43(4):723-726. Not sensitivity or specificity of an identified test. [pmid: 9558026].
Lerner A, Gruener N, Iancu T C. Serum carnitine concentrations in coeliac disease. Gut. 1993;34(7):933-935. Not sensitivity or specificity of an identified test. [pmid: 8344581]. [pmcid: 1374228].
Lernmark A. Molecular biology of IDDM. Diabetologia. 1994;37(Suppl 2):s73-s81. Not sensitivity or specificity of an identified test. [pmid: 7867882].
Lernmark A, Kloppel G, Stenger D, et al. Heterogeneity of islet pathology in two infants with recent onset diabetes mellitus. Virchows Arch. 1995;425(6):631-640. Not sensitivity or specificity of an identified test. [pmid: 7697219].
Leslie D, Lipsky P, Louis Notkins A. Autoantibodies as predictors of disease. J Clin Invest. 2001;108(10):1417-1422. Not sensitivity or specificity of an identified test. [pmid: 11714731]. [pmcid: 209428].
Lesort M, Attanavanich K, Zhang J, et al. Distinct nuclear localization and activity of tissue transglutaminase. Journal of Biological Chemistry. 1998;273(20):11991-11994. Not sensitivity or specificity of an identified test. [pmid: 9575137].
Lesort M, Chun W, Johnson G V, et al. Tissue transglutaminase is increased in Huntington's disease brain. Journal of Neurochemistry. 1999;73(5):2018-2027. Not sensitivity or specificity of an identified test. [pmid: 10537061].
Lesort M, Tucholski J, Miller M L, et al. Tissue transglutaminase: a possible role in neurodegenerative diseases. Progress in Neurobiology. 2000;61(5):439-463. Not sensitivity or specificity of an identified test. [pmid: 10748319].
Lesort M, Tucholski J, Zhang J, et al. Impaired mitochondrial function results in increased tissue transglutaminase activity in situ. Journal of Neurochemistry. 2000;75(5):1951-1961. Not sensitivity or specificity of an identified test. [pmid: 11032884].
Lesort Mathieu, Chun Wanjoo, Tucholski Janusz, et al. Does tissue transglutaminase play a role in Huntington's disease?. Neurochemistry International. 2002;40(1):37-52. Not sensitivity or specificity of an identified test. [pmid: 11738472].
Lesort Mathieu, Lee Matthew, Tucholski Janusz, et al. Cystamine inhibits caspase activity. Implications for the treatment of polyglutamine disorders. Journal of Biological Chemistry. 2002;278(6):3825-3830. Not sensitivity or specificity of an identified test. [pmid: 12458211].
Lessof M H, Kemeny D M, Price J F. IgG antibodies to food in health and disease. Allergy Proc. 1991;12(5):305-307. Not sensitivity or specificity of an identified test. [pmid: 1959767].
Leung A K C, Robson W M. Evaluating the child with chronic diarrhea. Am Fam Phys. 1996;53(2):635-643. Not sensitivity or specificity of an identified test.
Leuven F V, van den, Berghe H, et al. Primary amines inhibit recycling of alphainf 2M receptors in fibroblasts. Cell. 1980;20(1):37-43. Not sensitivity or specificity of an identified test. [pmid: 6156003].
Levenson S D, Austin R K, Dietler M D, et al. Specificity of antigliadin antibody in celiac disease. Gastroenterology. 1985;89(1):1-5. Not sensitivity or specificity of an identified test. [pmid: 4007398].
Levine A, Bujanover Y, Reif S, et al. Comparison of assays for anti-endomysial and anti-transglutaminase antibodies for diagnosis of pediatric celiac disease. Israel Medical Association Journal - Imaj. 2000;2(2):122-125. Unable to obtain full article.
Levine R A. Steatorrhea induced by para-aminosalicylic acid. Annals of Internal Medicine. 1968;68(6):1265-1270. Not sensitivity or specificity of an identified test. [pmid: 5673168].
Levitt M L, Gazdar A F, Oie H K, et al. Cross-linked envelope-related markers for squamous differentiation in human lung cancer cell lines. Cancer Research. 1990;50(1):120-128. Not sensitivity or specificity of an identified test. [pmid: 1967140].
Lewis C, Book L, Black J, et al. Celiac disease and human leukocyte antigen genotype: accuracy of diagnosis in self-diagnosed individuals, dosage effect, and sibling risk. Journal of Pediatric Gastroenterology and Nutrition. 2000;31(1):22-27. Improper control group. [pmid: 10896066].
Lewis K B, Teller D C, Fry J, et al. Crosslinking kinetics of the human transglutaminase, factor XIII[A2], acting on fibrin gels and gamma-chain peptides. Biochemistry. 1997;36(5):995-1002. Not sensitivity or specificity of an identified test. [pmid: 9033388].
Lewis-Jones M S, Barnes R M R, Macfarlane A W, et al. Frequency and isotype distribution of serum antibodies reactive with dietary proteins in adults with chronic urticaria. Clin Exp Dermatol. 1987;12(6):419-423. Not sensitivity or specificity of an identified test. [pmid: 3504749].
Li Voon, Chong J S W, Leong K S, et al. Is coeliac disease more prevalent in young adults with coexisting Type 1 diabetes mellitus and autoimmune thyroid disease compared with those with Type 1 diabetes mellitus alone?. Diabetic Medicine - a Journal of the British Diabetic Association. 2002;19(4):334-337. Not sensitivity or specificity of an identified test. [pmid: 11943007].
Licastro F, Mariani R A, Faldella G, et al. Immune-endocrine status and coeliac disease in children with Down Syndrome: Relationships with zinc and cognitive efficiency. Brain Res Bull. 2001;55(2):313-317. Not sensitivity or specificity of an identified test. [pmid: 11470333].
Lidang Jensen M, Johansen P. Immunocytochemical staining of serous effusions: an additional method in the routine cytology practice?. Cytopathology - Official Journal of the British Society for Clinical Cytology. 1994;5(2):93-103. Not sensitivity or specificity of an identified test. [pmid: 8038428].
Lie B A, Sollid L M, Ascher H, et al. A gene telomeric of the HLA class I region is involved in predisposition to both type 1 diabetes and coeliac disease. Tissue Antigens. 1999;54(2):162-168. Not sensitivity or specificity of an identified test. [pmid: 10488743].
Lifschitz C H, Polanco I, Lobb K. The urinary excretion of polyethylene glycol as a test for mucosal integrity in children with celiac disease: comparison with other noninvasive tests. Journal of Pediatric Gastroenterology and Nutrition. 1989;9(1):49-57. Not sensitivity or specificity of an identified test. [pmid: 2778569].
Lilley G R, Griffin M, Bonner P L. Assays for the measurement of tissue transglutaminase (type II) mediated protein crosslinking via epsilon-(gamma-glutamyl) lysine and N',N'-bis (gamma-glutamyl) polyamine linkages using biotin labelled casein. Journal of Biochemical and Biophysical Methods. 1997;34(1):31-43. Not sensitivity or specificity of an identified test. [pmid: 9089382].
Lim S D, Bae S I, Kim I G, et al. Tissue transglutaminase is not increased during apoptosis of HT-1080 human fibrosarcoma cells. Experimental and Toxicologic Pathology - Official Journal of the Gesellschaft Fur Toxikologische Pathologie. 1998;50(1):79-82. Not sensitivity or specificity of an identified test. [pmid: 9570506].
Lin H J, Rotter J I, Conte W J. Use of HLA marker associations and HLA haplotype linkage to estimate disease risks in families with gluten-sensitive enteropathy. Clinical Genetics. 1985;28(3):185-198. Not sensitivity or specificity of an identified test. [pmid: 3877582].
Lin L, Tokunaga K, Nakajima F, et al. Both HLA-B*1301 and B*1302 exist in Asian populations and are associated with different haplotypes. Hum Immunol. 1995;43(1):51-56. Not sensitivity or specificity of an identified test. [pmid: 7499177].
Lin X R, Wilkinson D I, Farber E M. Camptothecin induces differentiation, tissue transglutaminase and apoptosis in cultured keratinocytes. Experimental Dermatology. 1998;7(4):179-183. Not sensitivity or specificity of an identified test. [pmid: 9758415].
Linaker B D, Calam J. Is jejunal biopsy valuable in the elderly?. Age and Ageing. 1978;7(4):244-245. Not sensitivity or specificity of an identified test. [pmid: 727074].
Lindberg J, Ahren C, Iwarson S. Intestinal villous atrophy in chronic active hepatitis. Scandinavian Journal of Gastroenterology. 1979;14(8):1015-1018. Not sensitivity or specificity of an identified test. [pmid: 531508].
Lindberg J, Ahren Chr, Jonsson J. Gluten-free diet in chronic active hepatitis associated with intestinal villous atrophy. Hepato-Gastroenterology. 1982;29(2):52-54. Not sensitivity or specificity of an identified test. [pmid: 7084883].
Lindberg T, Norden A, Josefsson L. Intestinal dipeptidases. Dipeptidase activities in small intestinal biopsy specimens from a clinical material. Scandinavian Journal of Gastroenterology. 1968;3(2):177-182. Not sensitivity or specificity of an identified test. [pmid: 5711481].
Lindgren S, Sjoberg K, Eriksson S. Unsuspected coeliac disease in chronic ‘cryptogenic’ liver disease. Scandinavian Journal of Gastroenterology. 1994;29(7):661-664. Not sensitivity or specificity of an identified test. [pmid: 7939405].
Lindh E, Ljunghall S, Larsson K, et al. Screening for antibodies against gliadin in patients with osteoporosis. Journal of Internal Medicine. 1992;231(4):403-406. Not sensitivity or specificity of an identified test. [pmid: 1588266].
Lindqvist U, Rudsander A, Bostrom A, et al. IgA antibodies to gliadin and coeliac disease in psoriatic arthritis. Rheumatology (Oxford, England). 2002;41(1):31-37. Not sensitivity or specificity of an identified test. [pmid: 11792877].
Lindstrom C G. Millipore filter as support for fresh frozen sections of peroral biopsy specimens of small intestine. Acta Pathologica Et Microbiologica Scandinavica. 1969;77(3):555-556. Not sensitivity or specificity of an identified test. [pmid: 4192332].
Lindstrom J, Smith K J, Skelton H G, et al. Increased anticardiolipin antibodies associated with the development of anetoderma in HIV-1 disease. Military Medical Consortium for the Advancement of Retroviral research (MMCARR). International Journal of Dermatology. 1995;34(6):408-415. Not sensitivity or specificity of an identified test. [pmid: 7657440].
Linnestad P, Erichsen A, Fausa O, et al. The release of human pancreatic polypeptide, gastrin, gastric inhibitory polypeptide, and somatostatin in celiac disease related to the histological appearance of jejunal mucosa before and 1 year after gluten withdrawal. Scandinavian Journal of Gastroenterology. 1983;18(2):169-175. Not sensitivity or specificity of an identified test. [pmid: 6143393].
Linsenmayer T F, Long F, Nurminskaya M et al. Type X collagen and other up-regulated components of the avian hypertrophic cartilage program. Progress in Nucleic Acid Research and Molecular Biology 1998;6079–109. Not sensitivity or specificity of an identified test
Lio D, Bonanno C T, D'Anna C, et al. Gluten stimulation induces an in vitro expansion of peripheral blood T gamma delta cells from HLA-DQ2-positive subjects of families of patients with celiac disease. Experimental and Clinical Immunogenetics. 1998;15(1):46-55. Improper control group. [pmid: 9619399].
Lionetti P. The enteropathy of celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 2002;34(Suppl 1):S18-S21. Not sensitivity or specificity of an identified test. [pmid: 12082382].
Lionetti P, Pazzaglia A, Moriondo M, et al. Differing patterns of transforming growth factor-beta expression in normal intestinal mucosa and in active celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1999;29(3):308-313. Not sensitivity or specificity of an identified test. [pmid: 10467997].
Little A-M, Stern P L. Does HLA type predispose some individuals to cancer?. Mol Med Today. 1999;5(8):337-342. Not sensitivity or specificity of an identified test. [pmid: 10431166].
Little T M. Immunoglobulin levels in families with coeliac disease. Lancet. 1972;2(7774):400-401. Not sensitivity or specificity of an identified test. [pmid: 4117714].
Littlewood J M. Coeliac disease in childhood. Bailliere's Clinical Gastroenterology. 1995;9(2):295-327. Not sensitivity or specificity of an identified test. [pmid: 7549029].
Liu E, Bao F, Barriga K, et al. Fluctuating transglutaminase autoantibodies are related to histologic features of celiac disease. Clin Gastroenterol Hepatol. 2003;1(5):356-362. Improper control group. [pmid: 15017653].
Liu Edwin, Eisenbarth George S. Type 1A diabetes mellitus-associated autoimmunity. Endocrinology and Metabolism Clinics of North America. 2002;31(2):391-410, Vii. Not sensitivity or specificity of an identified test. [pmid: 12092457].
Liu J N, Kung W, Harpel P C, et al. Demonstration of covalent binding of lipoprotein(a) [Lp(a)] to fibrin and endothelial cells. Biochemistry. 1998;37(11):3949-3954. Not sensitivity or specificity of an identified test. [pmid: 9521716].
Liu J, Purdy L E, Rabinovitch S, et al. Major DQ8-restricted T-cell epitopes for human GAD65 mapped using human CD4, DQA1*0301, DQB1*0302 transgenic IA(null) NOD mice. Diabetes. 1999;48(3):469-477. Not sensitivity or specificity of an identified test. [pmid: 10078545].
Liu jianjun, Juo Suh, Holopainen Paivi, et al. Genomewide linkage analysis of celiac disease in Finnish families. American Journal of Human Genetics. 2002;70(1):51-59. Improper control group. [pmid: 11715113]. [pmcid: 384903].
Liu Shenping, Cerione Richard A, Clardy Jon. Structural basis for the guanine nucleotide-binding activity of tissue transglutaminase and its regulation of transamidation activity. Proceedings of the National Academy of Sciences of the United Statest of America. 2002;99(5):2743-2747. Not sensitivity or specificity of an identified test.
Liutu M. Helicobacter pylori and chronic urticaria. Forum Nordic Derm-Venerol. 2003;8(2):48-49. Not sensitivity or specificity of an identified test.
Liutu M, Kalimo K, Uksila J, et al. Etiologic aspects of chronic urticaria. International Journal of Dermatology. 1998;37(7):515-519. Not sensitivity or specificity of an identified test. [pmid: 9679692].
Lloyd-Still J D, Grand R J, Khaw K T, et al. The use of corticosteroids in celiac crisis. Journal of Pediatrics. 1972;81(6):1074-1081. Not sensitivity or specificity of an identified test. [pmid: 4566038].
Lock R J, Unsworth D J. Identifying immunoglobulin-A--deficient children and adults does not necessarily help the serologic diagnosis of coeliac disease. Journal of Pediatric Gastroenterology and Nutrition. 1999;28(1):81-83. Not sensitivity or specificity of an identified test. [pmid: 9890474].
Lock R J, Gilmour J E, Unsworth D J. Anti-tissue transglutaminase, anti-endomysium and anti-R1-reticulin autoantibodies-the antibody trinity of coeliac disease. Clinical and Experimental Immunology. 1999;116(2):258-262. Not sensitivity or specificity of an identified test. [pmid: 10337016]. [pmcid: 1905294].
Lock R J, Pitcher M C, Unsworth D J. IgA anti-tissue transglutaminase as a diagnostic marker of gluten sensitive enteropathy. Journal of Clinical Pathology. 1999;52(4):274-277. Improper control group. [pmid: 10474519]. [pmcid: 501332].
Loft D E. The epidemiology and diagnosis of coeliac disease. European Journal of Gastroenterology & Hepatology. 1993;5(2):69-72. Not sensitivity or specificity of an identified test.
Loft D E, Marsh M N, Crowe P T. Rectal gluten challenge and diagnosis of coeliac disease. Lancet. 1990;335(8701):1293-1295. Not sensitivity or specificity of an identified test. [pmid: 1976971].
Loft D E, Nwokolo C U, Ciclitira P J. The diagnosis of gluten sensitivity and coeliac disease--the two are not mutually inclusive. European Journal of Gastroenterology & Hepatology. 1998;10(11):911-913. Review article. [pmid: 9872611].
Logan R F. Screening for coeliac disease--has the time come for mass screening?. Acta paediatrica (Oslo, Norway : 1992).Supplement. 1996;41215–19. Not sensitivity or specificity of an identified test
Logan R F A, Howarth G F, West J, et al. How often is a positive faecal occult blood test the result of coeliac disease?. European Journal of Gastroenterology & Hepatology. 2003;15(10):1097-1100. Not sensitivity or specificity of an identified test. [pmid: 14501618].
Logan R F, Rifkind E A, Busuttil A, et al. Prevalence and “incidence” of celiac disease in Edinburgh and the Lothian region of Scotland. Gastroenterology. 1986;90(2):334-342. Not sensitivity or specificity of an identified test. [pmid: 3484455].
Lohiniemi S, Maki M, Kaukinen K, et al. Gastrointestinal symptoms rating scale in coeliac disease patients on wheat starch-based gluten-free diets. Scandinavian Journal of Gastroenterology. 2000;35(9):947-949. Not sensitivity or specificity of an identified test. [pmid: 11063154].
Lojda Z. Proteinases in pathology. Usefulness of histochemical methods. Journal of Histochemistry and Cytochemistry - Official Journal of the Histochemistry Society. 1981;29(3a Suppl):481-493. Not sensitivity or specificity of an identified test.
Lojda Z, Gossrau R. Histochemical demonstration of enteropeptidase activity. New method with a synthetic substrate and its comparison with the trypsinogen procedure. Histochemistry. 1983;78(2):251-270. Not sensitivity or specificity of an identified test. [pmid: 6409850].
Lojda Z, Fric P, Jodl J et al. Cytochemistry of the human jejunal mucosa in the norm and in malabsorption syndrome. Current Topics in Pathology 1970;521–63. Not sensitivity or specificity of an identified test
Lojda Z, Havrankova E, Slaby J. Histochemical demonstration of the intestinal hetero beta galactosidase (glucosidase). Histochemistry. 1974;42(3):271-286. Not sensitivity or specificity of an identified test. [pmid: 4218224].
Lokshin A, Mayotte J E, Levitt M L. Mechanism of interferon beta-induced squamous differentiation and programmed cell death in human non-small-cell lung cancer cell lines. Journal of the National Cancer Institute. 1995;87(3):206-212. Not sensitivity or specificity of an identified test. [pmid: 7707408].
Lokshin Anna E, Kalinski Pawel, Sassi R, et al. Differential regulation of maturation and apoptosis of human monocyte-derived dendritic cells mediated by MHC class II. International Immunology. 2002;14(9):1027-1037. Not sensitivity or specificity of an identified test. [pmid: 12202400].
Lomoschitz F, Schima W, Schober E, et al. Enteroclysis in adult celiac disease: diagnostic value of specific radiographic features. European Radiology. 2002;13(4):890-896. Not sensitivity or specificity of an identified test. [pmid: 12664131].
Londei M. The external world of gluten and autoimmunity. Gut. 2001;49(4):463-464. Not sensitivity or specificity of an identified test. [pmid: 11559639]. [pmcid: 1728462].
Londei M, Quaratino S, Maiuri L. Celiac disease: A model autoimmune disease with gene therapy applications. Gene Ther. 2003;10(10):835-843. Not sensitivity or specificity of an identified test. [pmid: 12732869].
Long F R, Kramer S S, Markowitz R I, et al. Duodenitis in children: Correlation of radiologic findings with endoscopic and pathologic findings. Radiology. 1998;206(1):103-108. Not sensitivity or specificity of an identified test. [pmid: 9423658].
Lopes J M, Bjerkehagen B, Holm R, et al. Immunohistochemical profile of synovial sarcoma with emphasis on the epithelial-type differentiation. A study of 49 primary tumours, recurrences and metastases. Pathology, Research and Practice. 1994;190(2):168-177. Not sensitivity or specificity of an identified test. [pmid: 7520165].
Lopez-Rodriguez M J, Canal Macias M L, Lavado Garcia J M, et al. Epidemiological changes in diagnosed coeliac disease in a population of Spanish children. Acta Paediatr Int J Paediatr. 2003;92(2):165-169. Not sensitivity or specificity of an identified test.
Lopez-Vazquez A, Rodrigo L, Fuentest D, et al. MHC class I chain related gene A (MICA) modulates the development of coeliac disease in patients with the high risk heterodimer DQA1*0501/DQB1*0201. Gut. 2002;50(3):336-340. Not sensitivity or specificity of an identified test. [pmid: 11839711]. [pmcid: 1773124].
Lopez-Vazquez Antonio, Rodrigo Luis, Fuentes Dolores, et al. MICA-A5. 1 allele is associated with atypical forms of celiac disease in HLA-DQ2-negative patients. Immunogenetics. 2002;53(1011):989-991. Not sensitivity or specificity of an identified test. [pmid: 11862400].
Lorand L. Post-translational pathways for generating epsilon(gamma-glutamyl)lysine cross-links. Annals of the New York Academy of Sciences 1983;42110–27. Not sensitivity or specificity of an identified test
Lorand L, Bjerrum O J, Hawkins M, et al. Degradation of transmembrane proteins in Ca2+-enriched human erythrocytes. An immunochemical study. Journal of Biological Chemistry. 1983;258(8):5300-5305. Not sensitivity or specificity of an identified test. [pmid: 6403545].
Lorand L, Dailey J E, Turner P M. Fibronectin as a carrier for the transglutaminase from human erythrocytes. Proceedings of the National Academy of Sciences of the United Statest of America. 1988;85(4):1057-1059. Not sensitivity or specificity of an identified test.
Lorand L, Murthy S N, Velasco P T, et al. Identification of transglutaminase substratest in inside-out vesicles from human erythrocytes: immunoblotting with anti-dansyl antibody. Biochemical and Biophysical Research Communications. 1986;134(2):685-689. Not sensitivity or specificity of an identified test. [pmid: 2868715].
Lorand L, Parameswaran K N, Velasco P T, et al. Biotinylated peptides containing a factor XIIIa or a tissue transglutaminase-reactive glutaminyl residue that block protein cross-linking phenomena by becoming incorporated into amine donor sites. Bioconjugate Chemistry. 1992;3(1):37-41. Not sensitivity or specificity of an identified test. [pmid: 1352131].
Lord C, MacGregor G A. Coeliac disease in identical twin infants. Postgraduate Medical Journal. 1981;57(672):658-659. Not sensitivity or specificity of an identified test. [pmid: 6950371].
Lorini R, Larizza D, Scotta M S, et al. HLA in Graves' disease coexistent with coeliac disease. European Journal of Pediatrics. 1986;145(3):241. Not sensitivity or specificity of an identified test. [pmid: 3769988].
Lorini R, Scaramuzza A, Vitali L, et al. Clinical aspects of coeliac disease in children with insulin-dependent diabetes mellitus. Journal of Pediatric Endocrinology & Metabolism - Jpem. 1996;9(Suppl 1):101-111. Not sensitivity or specificity of an identified test. [pmid: 8887160].
Lorini R, Scotta M S, Cortona L, et al. Celiac disease and type I (insulin-dependent) diabetes mellitus in childhood: follow-up study. Journal of Diabetes and Its Complications. 1996;10(3):154-159. Not sensitivity or specificity of an identified test. [pmid: 8807465].
Lotze U, Busch H J, Aschoff A, et al. Damaged myocytest as detected by the colocalization of DNA fragmentation and tissue transglutaminase and their prognostic significance in enterovirus-associated dilated cardiomyopathy. European Journal of Clinical Investigation. 2001;31(9):744-755. Not sensitivity or specificity of an identified test. [pmid: 11589716].
Louis E J, Payami H, Klitz W et al. A synergistic three allele model for the HLA-linked components of coeliac disease predisposition. Genetic Epidemiology.Supplement 1986;1277–282. Not sensitivity or specificity of an identified test
Louis E J, Thomson G, Payami H. The affected sib method. II. The intermediate model. Annals of Human Genetics. 1983;47(Pt 3):225-243. Not sensitivity or specificity of an identified test. [pmid: 6688509].
Louka A S, Sollid L M. HLA in coeliac disease: Unravelling the complex genetics of a complex disorder. Tissue Antigens. 2003;61(2):105-117. Not sensitivity or specificity of an identified test. [pmid: 12694579].
Louka A S, Moodie S J, Karell K, et al. A collaborative European search for non-DQA1 *05-DQB1 *02 Celiac disease loci on HLA-Dr3 haplotypes: Analysis of transmission from homozygous parents. Hum Immunol. 2003;64(3):350-358. Not sensitivity or specificity of an identified test. [pmid: 12651074].
Louka A S, Nilsson S, Olsson M, et al. HLA in coeliac disease families: a novel test of risk modification by the ‘other’ haplotype when at least one DQA1*05-DQB1*02 haplotype is carried. Tissue Antigens. 2002;60(2):147-154. Not sensitivity or specificity of an identified test. [pmid: 12392509].
Louka A S, Torinsson Naluai A, D'Alfonso S, et al. The IL12B gene does not confer susceptibility to coeliac disease. Tissue Antigens. 2002;59(1):70-72. Not sensitivity or specificity of an identified test. [pmid: 11972887].
Louka Andrew S, Lie Benedicte A, Talseth Bente, et al. Coeliac disease patients carry conserved HLA-DR3-DQ2 haplotypes revealed by association of TNF alleles. Immunogenetics. 2003;55(5):339-343. Not sensitivity or specificity of an identified test. [pmid: 12845502].
Lu S, Davies P J. Regulation of the expression of the tissue transglutaminase gene by DNA methylation. Proceedings of the National Academy of Sciences of the United Statest of America. 1997;94(9):4692-4697. Not sensitivity or specificity of an identified test.
Lu S, Saydak M, Gentile V, et al. Isolation and characterization of the human tissue transglutaminase gene promoter. Journal of Biological Chemistry. 1995;270(17):9748-9756. Not sensitivity or specificity of an identified test. [pmid: 7730352].
Lu X, Xie W, Reed D, et al. Nonsteroidal antiinflammatory drugs cause apoptosis and induce cyclooxygenases in chicken embryo fibroblasts. Proc Natl Acad Sci U S A. 1995;92(17):7961-7965. Not sensitivity or specificity of an identified test. [pmid: 7644521]. [pmcid: 41266].
Lucas D L, Tanuma S, Davies P J, et al. Maturation of human promyelocytic leukemia cells induced by nicotinamide: evidence of a regulatory role for ADP-ribosylation of chromosomal proteins. Journal of Cellular Physiology. 1984;121(2):334-340. Not sensitivity or specificity of an identified test. [pmid: 6149227].
Lucas M L, Cooper B T, Lei F H, et al. Acid microclimate in coeliac and Crohn's disease: a model for folate malabsorption. Gut. 1978;19(8):735-742. Not sensitivity or specificity of an identified test. [pmid: 28271]. [pmcid: 1412145].
Luconi M, Muratori M, Maggi M, et al. Uteroglobin and transglutaminase modulate human sperm functions. Journal of Andrology. 2000;21(5):676-688. Not sensitivity or specificity of an identified test. [pmid: 10975415].
Ludvigsson J F, Falth-Magnusson K, Ludvigsson J. Tissue transglutaminase auto-antibodies in cord blood from children to become celiacs. Scandinavian Journal of Gastroenterology. 2001;36(12):1279-1283. Not sensitivity or specificity of an identified test. [pmid: 11761017].
Lukacova D, Matsueda G R, Haber E, et al. Inhibition of factor XIII activation by an anti-peptide monoclonal antibody. Biochemistry. 1991;30(42):10164-10170. Not sensitivity or specificity of an identified test. [pmid: 1681898].
Lundin K E A. Coeliac disease--all questions answered?. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver 2002;34(3):238–242. Not sensitivity or specificity of an identified test
Lundin K E A. HLA-DQ8 as an Ir gene in coeliac disease. Gut. 2003;52(1):7-8. Review article. [pmid: 14570737]. [pmcid: 1773536].
Lundin K E A, Sollid L M. Gliadin peptide specific intestinal T cells in coeliac disease. Gut. 2003;52(2):162. Not sensitivity or specificity of an identified test. [pmid: 12524389]. [pmcid: 1774969].
Lundin K E A, Nilsen E M, Scott H G, et al. Oats induced villous atrophy in coeliac disease. Gut. 2003;52(11):1649-1652. Not sensitivity or specificity of an identified test. [pmid: 14570737]. [pmcid: 1773854].
Lundin K E, Gjertsen H A, Scott H, et al. Function of DQ2 and DQ8 as HLA susceptibility molecules in celiac disease. Human Immunology. 1994;41(1):24-27. Not sensitivity or specificity of an identified test. [pmid: 7836060].
Lundin K E, Qvigstad E, Sollid L M, et al. Alloreactive T cells recognizing determinants dependent on the DQ beta chain of DQw2. Tissue Antigens. 1989;34(5):312-316. Not sensitivity or specificity of an identified test. [pmid: 2483467].
Lundin K E, Scott H, Fausa O, et al. T cells from the small intestinal mucosa of a DR4, DQ7/DR4, DQ8 celiac disease patient preferentially recognize gliadin when presented by DQ8. Human Immunology. 1994;41(4):285-291. Not sensitivity or specificity of an identified test. [pmid: 7883596].
Lundin K E, Scott H, Hansen T, et al. Gliadin-specific, HLA-DQ(alpha 1*0501,beta 1*0201) restricted T cells isolated from the small intestinal mucosa of celiac disease patients. Journal of Experimental Medicine. 1993;178(1):187-196. Not sensitivity or specificity of an identified test. [pmid: 8315377].
Lundin K E, Sollid L M, Anthonsen D, et al. Heterogeneous reactivity patterns of HLA-DQ-restricted, small intestinal T-cell clones from patients with celiac disease. Gastroenterology. 1997;112(3):752-759. Not sensitivity or specificity of an identified test. [pmid: 9041236].
Lundin K E, Sollid L M, Qvigstad E, et al. T lymphocyte recognition of a celiac disease-associated cis- or trans-encoded HLA-DQ alpha/beta-heterodimer. Journal of Immunology (Baltimore, Md -1950). 1990;145(1):136-139. Not sensitivity or specificity of an identified test. [pmid: 1972714].
Luostarinen L K, Collin P O, Peraaho M J, et al. Coeliac disease in patients with cerebellar ataxia of unknown origin. Annals of Medicine. 2001;33(6):445-449. Not sensitivity or specificity of an identified test. [pmid: 11585106].
Luostarinen L, Dastidar P, Collin P, et al. Association between coeliac disease, epilepsy and brain atrophy. European Neurology. 2001;46(4):187-191. Not sensitivity or specificity of an identified test. [pmid: 11721124].
Luyet C, Burri P H, Schittny J C. Suppression of cell proliferation and programmed cell death by dexamethasone during postnatal lung development. Am J Physiol Lung Cell Mol Physiol. 2002;282(3 263):L477-L483. Not sensitivity or specificity of an identified test. [pmid: 11839541].
Luzi Giuseppe, Zullo Angelo, Iebba Filippo, et al. Duodenal pathology and clinical-immunological implications in common variable immunodeficiency patients. American Journal of Gastroenterology. 2003;98(1):118-121. Not sensitivity or specificity of an identified test. [pmid: 12526946].
Lycke N, Kilander A, Nilsson L A, et al. Production of antibodies to gliadin in intestinal mucosa of patients with coeliac disease: a study at the single cell level. Gut. 1989;30(1):72-77. Not sensitivity or specificity of an identified test. [pmid: 2920930]. [pmcid: 1378234].
Lynch D A, Sobala G M, Dixon M F, et al. Lymphocytic gastritis and associated small bowel disease: a diffuse lymphocytic gastroenteropathy?. Journal of Clinical Pathology. 1995;48(10):939-945. Not sensitivity or specificity of an identified test. [pmid: 8537495]. [pmcid: 502952].
Macaubas C, Hallmayer J, Kalil J, et al. Extensive polymorphism of a (CA)(n) microsatellite located in the HLA- DQA1/DQB1 class II region. Hum Immunol. 1995;42(3):209-220. Not sensitivity or specificity of an identified test. [pmid: 7759308].
MacDonald T T. Epithelial proliferation in response to gastrointestinal inflammation. Annals of the New York Academy of Sciences 1992;664202–209. Not sensitivity or specificity of an identified test
MacDonald T T. The role of activated T lymphocytes in gastrointestinal disease. Clinical and Experimental Allergy - Journal of the British Society for Allergy and Clinical Immunology. 1990;20(3):247-252. Not sensitivity or specificity of an identified test. [pmid: 2115814].
MacDonald T T. Evidence for cell-mediated hypersensitivity as an important pathogenetic mechanism in food intolerance. Clin Exp Allergy Suppl. 1995;25(1):10-13. Not sensitivity or specificity of an identified test.
MacDonald T T, Spencer J. Cell-mediated immune injury in the intestine. Gastroenterology Clinics of North America. 1992;21(2):367-386. Not sensitivity or specificity of an identified test. [pmid: 1355077].
MacDonald T T, Spencer J. The role of activated T cells in transformed intestinal mucosa. Digestion. 1990;46(Suppl 2):290-296. Not sensitivity or specificity of an identified test. [pmid: 2262061].
Machulla H K G, Muller L P, Schaaf A, et al. Association of chronic lymphocytic leukemia with specific alleles of the HLA-DR4:DR53:DQ8 haplotype in German patients. Int J Cancer. 2001;92(2):203-207. Not sensitivity or specificity of an identified test. [pmid: 11291046].
Mack D G, Johnson J J, Roberts F, et al. HLA-class II genes modify outcome of Toxoplasma gondii infection. Int J Parasitol. 1999;29(9):1351-1358. Not sensitivity or specificity of an identified test. [pmid: 10579423].
Mack R, Chowdary D, Samaan P, et al. Prevalence of CTLA-4 polymorphism A49G in Ashkenazi Jews. Genet test. 2001;5(3):269-271. Not sensitivity or specificity of an identified test. [pmid: 11788096].
Mackenzie I R, Gilbert J J. Cysts of the neuraxis of endodermal origin. Journal of Neurology, Neurosurgery, and Psychiatry. 1991;54(7):572-575. Not sensitivity or specificity of an identified test. [pmid: 1895117].
Mackey J, Treem W R, Worley G, et al. Frequency of celiac disease in individuals with Down syndrome in the United States. Clinical Pediatrics. 2001;40(5):249-252. Not sensitivity or specificity of an identified test. [pmid: 11388673].
Mackintosh P, Asquith P. HLA and coeliac disease. British Medical Bulletin. 1978;34(3):291-294. Not sensitivity or specificity of an identified test. [pmid: 102394].
Macpherson A J S, Bjarnason I, Peters T J. The subcellular distribution and levels of calmodulin in jejunal biopsies from control subjects and patients with coeliac disease. Clin Chim Acta. 1986;159(2):133-138. Not sensitivity or specificity of an identified test. [pmid: 3769205].
Mader R, Adawi M, Schonfeld S. Malabsorption in systemic lupus erythematosus. Clinical and Experimental Rheumatology. 1997;15(6):659-661. Not sensitivity or specificity of an identified test. [pmid: 9444423].
Madi A, Punyiczki M, di Rao M, et al. Biochemical characterization and localization of transglutaminase in wild-type and cell-death mutants of the nematode Caenorhabditis elegans. European Journal of Biochemistry / Febs. 1998;253(3):583-590. Not sensitivity or specificity of an identified test. [pmid: 9654053].
Maffei H V, Kingston D, Hill I D, et al. Histopathologic changes and the immune response within the jejunal mucosa in infants and children. Pediatric Research. 1979;13(6):733-736. Not sensitivity or specificity of an identified test. [pmid: 384350].
Magaudda A, Dalla Bernadina B, De Marco P, et al. Bilateral occipital calcification, epilepsy and coeliac disease: Clinical and neuroimaging features of a new syndrome. J Neurol Neurosurg Psychiatry. 1993;56(8):885-889. Not sensitivity or specificity of an identified test. [pmid: 8350105].
Magaudda L, Anastasi G, Arco A, et al. Scanning electron microscopy of histological relapse after gluten-challenge in coeliac disease. Acta Paediatr Scand. 1989;78(4):549-554. Not sensitivity or specificity of an identified test. [pmid: 2782070].
Magazzu G, Bottari M, Tuccari G, et al. Upper gastrointestinal endoscopy can be a reliable screening tool for celiac sprue in adults. Journal of Clinical Gastroenterology. 1994;19(3):255-257. Not sensitivity or specificity of an identified test. [pmid: 7806840].
Maggio N, Sellitti S, Capano C P, et al. Tissue-transglutaminase in rat and human brain: light and electron immunocytochemical analysis and in situ hybridization study. Brain Research Bulletin. 2001;56(34):173-182. Not sensitivity or specificity of an identified test. [pmid: 11719248].
Magliocca F M, Bonamico M, Petrozza V, et al. Usefulness of endoscopic small intestinal biopsies in children with coeliac disease. Italian Journal of Anatomy and Embryology = Archivio Italiano Di Anatomia Ed Embriologia. 2001;106(2 Suppl 1):329-335. Unable to extract data. [pmid: 11729974].
Magliocca F M, Bonamico M, Petrozza V, et al. A new morphological classification during follow-up in patients with celiac disease: a three-dimensional observation by scanning electron microscopy. Histology and Histopathology. 1996;11(2):343-350. Unable to extract data. [pmid: 8861756].
Magnaldo T, Bernerd F, Asselineau D, et al. Expression of loricrin is negatively controlled by retinoic acid in human epidermis reconstructed in vitro. Differentiation. 1992;49(1):39-46. Not sensitivity or specificity of an identified test. [pmid: 1378029].
Mahadeva S, Wyatt J I, Howdle P D. Is a raised intraepithelial lymphocyte count with normal duodenal villous architecture clinically relevant?. Journal of Clinical Pathology. 2002;55(6):424-428. Not sensitivity or specificity of an identified test. [pmid: 12037023]. [pmcid: 1769667].
Mahmoud F, Alsaleh Q, Abul H, et al. Association of major histocompatibility complex with psoriasis vulgaris in adult kuwaitis. Med Princ Pract. 1998;7(4):261-263. Not sensitivity or specificity of an identified test.
Mahon J, Blair G E, Wood G M, et al. Is persistent adenovirus 12 infection involved in coeliac disease? A search for viral DNA using the polymerase chain reaction. Gut. 1991;32(10):1114-1116. Not sensitivity or specificity of an identified test. [pmid: 1955164]. [pmcid: 1379369].
Mahoney S-A, Wilkinson M, Smith S, et al. Stabilization of neuritest in cerebellar granule cells by transglutaminase activity: Identification of midkine and galectin-3 as substrates. Neuroscience. 2000;101(1):141-155. Not sensitivity or specificity of an identified test. [pmid: 11068143].
Mainardi Elsa, Montanelli Alessandro, Dotti Maria, et al. Thyroid-related autoantibodies and celiac disease: a role for a gluten-free diet?. Journal of Clinical Gastroenterology. 2002;35(3):245-248. Not sensitivity or specificity of an identified test. [pmid: 12192201].
Mainguet P. Staining methods of the duodenal and intestinal mucosae: METHODES DE COLORATIONS VITALES DES MUQUEUSES DUODENALES ET INTESTINALES. Acta Endosc. 2001;31(2):179-182. Not sensitivity or specificity of an identified test.
Maiuri L, Auricchio S, Coletta S, et al. Blockage of T-cell costimulation inhibits T-cell action in celiac disease. Gastroenterology. 1998;115(3):564-572. Not sensitivity or specificity of an identified test. [pmid: 9721153].
Maiuri L, Ciacci C, Auricchio S, et al. Interleukin 15 mediatest epithelial changes in celiac disease. Gastroenterology. 2000;119(4):996-1006. Not sensitivity or specificity of an identified test. [pmid: 11040186].
Maiuri L, Ciacci C, Raia V, et al. FAS engagement drives apoptosis of enterocytes of coeliac patients. Gut. 2001;48(3):418-424. Not sensitivity or specificity of an identified test. [pmid: 11171836]. [pmcid: 1760155].
Maiuri L, Ciacci C, Vacca L, et al. IL-15 drives the specific migration of CD94+ and TCR-gammadelta+ intraepithelial lymphocytes in organ cultures of treated celiac patients. American Journal of Gastroenterology. 2001;96(1):150-156. Not sensitivity or specificity of an identified test. [pmid: 11197245].
Maiuri L, Picarelli A, Boirivant M, et al. Definition of the initial immunologic modifications upon in vitro gliadin challenge in the small intestine of celiac patients. Gastroenterology. 1996;110(5):1368-1378. Not sensitivity or specificity of an identified test. [pmid: 8613040].
Maiuri L, Troncone R, Fais S, et al. Crypt epithelial cells express the 4F2 antigen in untreated coeliac mucosa. Adv Exp Med Biol. 1995;371(B):1363-1365. Not sensitivity or specificity of an identified test. [pmid: 7502818].
Maiuri L, Troncone R, Mayer M, et al. In vitro activities of A-gliadin-related synthetic peptides: damaging effect on the atrophic coeliac mucosa and activation of mucosal immune response in the treated coeliac mucosa. Scandinavian Journal of Gastroenterology. 1996;31(3):247-253. Not sensitivity or specificity of an identified test. [pmid: 8833354].
Maiuri Luigi, Ciacci Carolina, Ricciardelli Ida, et al. Association between innate response to gliadin and activation of pathogenic T cells in coeliac disease. Lancet. 2003;362(9377):30-37. Not sensitivity or specificity of an identified test. [pmid: 12853196].
Maiuri M C, De Stefano D, Mele G, et al. Nuclear factor kappaB is activated in small intestinal mucosa of celiac patients. J Mol Med. 2003;81(6):373-379. Not sensitivity or specificity of an identified test. [pmid: 12743709].
Maki M. The humoral immune system in coeliac disease. Bailliere's Clinical Gastroenterology. 1995;9(2):231-249. Not sensitivity or specificity of an identified test. [pmid: 7549026].
Maki M. Tissue transglutaminase as the autoantigen of coeliac disease. Gut. 1997;41(4):565-566. Not sensitivity or specificity of an identified test. [pmid: 9391261]. [pmcid: 1891530].
Maki M. Coeliac disease and autoimmunity due to unmasking of cryptic epitopes?. Lancet. 1996;348(9034):1046-1047. Not sensitivity or specificity of an identified test. [pmid: 8874452].
Maki M. Immunopathogenesis of coeliac disease. Int J Immunopathol Pharmacol. 1997;10(2 SUPPL.):81-82. Not sensitivity or specificity of an identified test.
Maki M, Aine L, Lipsanen V, et al. Dental enamel defects in first-degree relatives of coeliac disease patients. Lancet. 1991;337(8744):763-764. Not sensitivity or specificity of an identified test. [pmid: 1672395].
Maki M, Hallstrom O, Huupponen T, et al. Increased prevalence of coeliac disease in diabetes. Archives of Disease in Childhood. 1984;59(8):739-742. Not sensitivity or specificity of an identified test. [pmid: 6476871].
Maki M, Hallstrom O, Vesikari T, et al. Evaluation of a serum IgA-class reticulin antibody test for the detection of childhood celiac disease. Journal of Pediatrics. 1984;105(6):901-905. Not sensitivity or specificity of an identified test. [pmid: 6502340].
Maki M, Holm K, Koskimies S, et al. Normal small bowel biopsy followed by coeliac disease. Archives of Disease in Childhood. 1990;65(10):1137-1141. Improper control group. [pmid: 2248506].
Maki M, Huupponen T, Holm K, et al. Seroconversion of reticulin autoantibodies predicts coeliac disease in insulin dependent diabetes mellitus. Gut. 1995;36(2):239-242. Not sensitivity or specificity of an identified test. [pmid: 7883223]. [pmcid: 1382410].
Maki M, Lahdeaho M L, Hallstrom O, et al. Postpubertal gluten challenge in coeliac disease. Archives of Disease in Childhood. 1989;64(11):1604-1607. Not sensitivity or specificity of an identified test. [pmid: 2604420].
Maki M, Sulkanen S, Collin P. Antibodies in relation to gluten intake. Digestive Diseases (Basel, Switzerland). 1998;16(6):330-332. Not sensitivity or specificity of an identified test. [pmid: 10207216].
Maki Markku, Mustalahti Kirsi, Kokkonen Jorma, et al. Prevalence of Celiac disease among children in Finland. New England Journal of Medicine. 2003;348(25):2517-2524. Not sensitivity or specificity of an identified test. [pmid: 12815137].
Maksimak M. A rapid, safe small bowel biopsy technique in children. Gastrointest Endosc. 1991;37(3):358-361. Not sensitivity or specificity of an identified test. [pmid: 2070989].
Malik A K, McGee J O. Alpha-1-antitrypsin immunoreactivity in the small bowel in coeliac disease. Malaysian Journal of Pathology. 1993;15(2):151-154. Not sensitivity or specificity of an identified test. [pmid: 8065178].
Malik A K, Burns J, McGee J O. Immunoperoxidase localization of fibronectin in small bowel mucosa. Indian Journal of Pathology & Microbiology. 1992;35(2):88-93. Not sensitivity or specificity of an identified test. [pmid: 1483722].
Malis F, Lojda Z, Fric P, et al. Disaccharidases in celiac disease and mucoviscidosis. Some correlations between histological, histochemical and biochemical studies. Digestion. 1972;5(1):40-48. Not sensitivity or specificity of an identified test. [pmid: 4550096].
Malizia G, Trejdosiewicz L K, Wood G M, et al. The microenvironment of coeliac disease: T cell phenotypes and expression of the T2 ‘T blast’ antigen by small bowel lymphocytes. Clinical and Experimental Immunology. 1985;60(2):437-446. Not sensitivity or specificity of an identified test. [pmid: 3159529]. [pmcid: 1577031].
Mallas E G, Williamson N, Cooper B T, et al. IgA class reticulin antibodies in relatives of patients with coeliac disease. Gut. 1977;18(8):647-650. Not sensitivity or specificity of an identified test. [pmid: 892611]. [pmcid: 1411703].
Mallet M. Coeliac disease in the very elderly. Cme J Geriatr Med. 2002;4(2):70-73. Not sensitivity or specificity of an identified test.
Maluenda C, Phillips A D, Briddon A, et al. Quantitative analysis of small intestinal mucosa in cow's milk-sensitive enteropathy. Journal of Pediatric Gastroenterology and Nutrition. 1984;3(3):349-356. Not sensitivity or specificity of an identified test. [pmid: 6737178].
Manabe K, Donaldson P T, Underhill J A, et al. DR3-DQ2-DPB1*0401 extended haplotype in autoimmune hepatitis. Hepatology. 1993;18(6):1334-1337. Not sensitivity or specificity of an identified test. [pmid: 8244257].
Mandal A, Mayberry J. How common is celiac disease in South America?. American Journal of Gastroenterology. 2000;95(3):579-580. Not sensitivity or specificity of an identified test. [pmid: 10710041].
Mandrusiak L M, Beitel L K, Wang X, et al. Transglutaminase potentiatest ligand-dependent proteasome dysfunction induced by polyglutamine-expanded androgen receptor. Hum Mol Genet. 2003;12(13):1497-1506. Not sensitivity or specificity of an identified test. [pmid: 12812978].
Manfras B J, Swinyard M, Rudert W A, et al. Altered CYP21 genes in HLA-haplotypes associated with congenital adrenal hyperplasia (CAH): A family study. Hum Genet. 1993;92(1):33-39. Not sensitivity or specificity of an identified test. [pmid: 8365724].
Mann D L, Katz S I, Nelson D L, et al. Specific B-cell antigens associated with gluten-sensitive enteropathy and dermatitis herpetiformis. Lancet. 1976;1(7951):110-111. Not sensitivity or specificity of an identified test. [pmid: 54633].
Mannering S I, Purcell A W, Honeyman M C, et al. Human T-cells recognise N-terminally Fmoc-modified peptide. Vaccine. 2003;21(2526):3638-3646. Not sensitivity or specificity of an identified test. [pmid: 12922093].
Mannion A, Stevens F M, McCarthy C F, et al. Extended major histocompatibility complex haplotypes in celiac patients in the west of Ireland. American Journal of Medical Genetics. 1993;45(3):373-377. Not sensitivity or specificity of an identified test. [pmid: 8434627].
Manousos O N, Economidou J C, Georgiadou D E, et al. Alpha-chain disease with clinical, immunological, and histological recovery. British Medical Journal. 1974;2(916):409-412. Not sensitivity or specificity of an identified test. [pmid: 4135071]. [pmcid: 1610468].
Mansbridge J N, Knappe A M. Changes in keratinocyte maturation during wound healing. J Invest Dermatol. 1987;89(3):253-263. Not sensitivity or specificity of an identified test. [pmid: 2442269].
Mantile G, Miele L, Cordella-Miele E, et al. Human Clara cell 10-kDa protein is the counterpart of rabbit uteroglobin. Journal of Biological Chemistry. 1993;268(27):20343-20351. Not sensitivity or specificity of an identified test. [pmid: 8104186].
Mantovani V, Corazza G R, Angelini G, et al. Molecular analysis of HLA-DQ A alleles in coeliac disease lack of a unique disease-associated sequence. Clinical and Experimental Immunology. 1991;83(1):74-78. Not sensitivity or specificity of an identified test. [pmid: 1671007]. [pmcid: 1535481].
Mantovani V, Corazza G R, Bragliani M, et al. Asp57-negative HLA DQ beta chain and DQA1*0501 allele are essential for the onset of DQw2-positive and DQw2-negative coeliac disease. Clinical and Experimental Immunology. 1993;91(1):153-156. Not sensitivity or specificity of an identified test. [pmid: 8419077]. [pmcid: 1554651].
Mantovani V, Corazza G R, Frisoni M, et al. HLA-DP polymorphism in northern Italian celiac patients. Tissue Antigens. 1992;40(4):182-186. Not sensitivity or specificity of an identified test. [pmid: 1361687].
Mantzaris G J, Tsirogianni A, Perivolioti E, et al. Sensitivity and specificity of serum IgA class endomysial antibody in the diagnosis of coeliac disease. Hell J Gastroenterol. 1996;8(4):308-311. Improper control group.
Manuel P D, Walker-Smith J A, France N E. Patchy enteropathy in childhood. Gut. 1979;20(3):211-215. Not sensitivity or specificity of an identified test. [pmid: 437554]. [pmcid: 1412306].
Marek A, Korzon M, Smiatacz T, et al. Attempt to evaluate activation of peripheral blood lymphocytes (CD69) after gluten challenge in children with coeliac disease. Med Sci Monit. 1998;4(5):821-825. Not sensitivity or specificity of an identified test.
Marek Andrzej, Brodzicki Jacek, Liberek Anna, et al. TGF-beta (transforming growth factor-beta) in chronic inflammatory conditions - a new diagnostic and prognostic marker?. Medical Science Monitor - International Medical Journal of Experimental and Clinical Research. 2002;8(7):Ra145-Ra151. Not sensitivity or specificity of an identified test. [pmid: 12118214].
Mariani P, Carsughi F, Spinozzi F, et al. Ligand-induced conformational changes in tissue transglutaminase: Monte Carlo analysis of small-angle scattering data. Biophysical Journal. 2000;78(6):3240-3251. Not sensitivity or specificity of an identified test. [pmid: 10828000]. [pmcid: 1300905].
Mariani P, Mazzilli M C, Margutti G, et al. Coeliac disease, enamel defects and HLA typing. Acta Paediatrica (Oslo, Norway - 1992). 1994;83(12):1272-1275. Not sensitivity or specificity of an identified test. [pmid: 7734869].
Mariani P, Viti M G, Montuori M, et al. The gluten-free diet: a nutritional risk factor for adolescents with celiac disease?. Journal of Pediatric Gastroenterology and Nutrition. 1998;27(5):519-523. Not sensitivity or specificity of an identified test. [pmid: 9822315].
Marinello D, Rapa A, Osello R, et al. Celiac disease screening: exploring the iceberg with salivary antigliadin antibodies. Journal of Pediatric Gastroenterology and Nutrition. 2001;32(2):227-228. Not sensitivity or specificity of an identified test. [pmid: 11321405].
Marks J, Shuster S. Dermatogenic enteropathy. Gut. 1970;11(4):292-298. Not sensitivity or specificity of an identified test. [pmid: 5430375]. [pmcid: 1411409].
Marks J, Shuster S. Intestinal malabsorption and the skin. Gut. 1971;12(11):938-947. Not sensitivity or specificity of an identified test. [pmid: 4943615]. [pmcid: 1411946].
Marks J, Shuster S. Skin disease and the gut. British Medical Journal. 1971;1(740):110-111. Not sensitivity or specificity of an identified test. [pmid: 5539165].
Marks J, Birkett D, Shuster S, et al. Small intestinal mucosal abnormalities in relatives of patients with dermatitis herpetiformis. Gut. 1970;11(6):493-497. Not sensitivity or specificity of an identified test. [pmid: 5430375]. [pmcid: 1553043].
Marley N J, Macartney J C, Ciclitira P J. HLA-DR, DP and DQ expression in the small intestine of patients with coeliac disease. Clinical and Experimental Immunology. 1987;70(2):386-393. Not sensitivity or specificity of an identified test. [pmid: 3322617]. [pmcid: 1542080].
Marn C S, Gore R M, Ghahremani G G. Duodenal manifestations of nontropical sprue. Gastrointestinal Radiology. 1986;11(1):30-35. Not sensitivity or specificity of an identified test. [pmid: 3943675].
Marren P, Yell J, Charnock F M, et al. The association between lichen sclerosus and antigens of the HLA system. British Journal of Dermatology. 1995;132(2):197-203. Not sensitivity or specificity of an identified test. [pmid: 7888355].
Marsh M N. Studies of intestinal lymphoid tissue: the cytology and electron microscopy of gluten-sensitive enteropathy, with particular reference to its immunopathology. Scandinavian Journal of Gastroenterology.Supplement 1981;7087–106. Not sensitivity or specificity of an identified test
Marsh M N. Studies of intestinal lymphoid tissue. XV. Histopathologic features suggestive of cell-mediated reactivity in jejunal mucosae of patients with dermatitis herpetiformis. Virchows Archiv. A, Pathological Anatomy and Histopathology. 1989;416(2):125-132. Not sensitivity or specificity of an identified test.
Marsh M N. Screening for latent gluten sensitivity: questions many, but answers few. European Journal of Gastroenterology & Hepatology. 1996;8(1):3-6. Not sensitivity or specificity of an identified test. [pmid: 8900901].
Marsh M N. Gluten, major histocompatibility complex, and the small intestine: A molecular and immunobiologic approach to the spectrum of gluten sensitivity (‘celiac sprue’). Gastroenterology. 1992;102(1):330-354. Not sensitivity or specificity of an identified test. [pmid: 1727768].
Marsh M N. Gluten sensitivity and latency: Can patterns of intestinal antibody secretion define the great ‘silent majority?’. Gastroenterology. 1993;104(5):1550-1553. Not sensitivity or specificity of an identified test. [pmid: 8482468].
Marsh M N. The immunopathology of the small intestinal reaction in gluten-sensitivity. Immunological Investigations. 1989;18(14):509-531. Not sensitivity or specificity of an identified test. [pmid: 2786501].
Marsh M N. The natural history of gluten sensitivity: Defining, refining and re-defining. Q J Med. 1995;88(1):9-13. Not sensitivity or specificity of an identified test.
Marsh M N. Transglutaminase, gluten and celiac disease: Food for thought. Nat Med. 1997;3(7):725-726. Not sensitivity or specificity of an identified test. [pmid: 9212095].
Marsh M N, Haeney M R. Studies of intestinal lymphoid tissue. VI. Proliferative response of small intestinal epithelial lymphocytes distinguishes gluten-from non-gluten-induced enteropathy. J Clin Pathol. 1983;36(2):149-160. Not sensitivity or specificity of an identified test. [pmid: 6826770]. [pmcid: 498142].
Marsh M N, Miller V. Studies of intestinal lymphoid tissue. VIII. Use of epithelial lymphocyte mitotic indices in differentiating untreated celiac sprue mucosa from other childhood enteropathies. Journal of Pediatric Gastroenterology and Nutrition. 1985;4(6):931-935. Unable to extract data. [pmid: 4067781].
Marsh M N, Bjarnason I, Shaw J, et al. Studies of intestinal lymphoid tissue. XIV--HLA status, mucosal morphology, permeability and epithelial lymphocyte populations in first degree relatives of patients with coeliac disease. Gut. 1990;31(1):32-36. Not sensitivity or specificity of an identified test. [pmid: 2318429]. [pmcid: 1378337].
Marsh M N, Loft D E, Garner V G, et al. Time/dose responses of coeliac mucosae to graded oral challenges with Frazer's fraction III of gliadin. European Journal of Gastroenterology & Hepatology. 1992;4(8):667-673. Not sensitivity or specificity of an identified test.
Marsh M N, Mathan M, Mathan V I. Studies of intestinal lymphoid tissue. VII. The secondary nature of lymphoid cell “activation” in the jejunal lesion of tropical sprue. American Journal of Pathology. 1983;112(3):302-312. Not sensitivity or specificity of an identified test. [pmid: 6614143]. [pmcid: 1916392].
Martelossi S, Zanatta E, Del Santo E et al. Dental enamel defects and screening for coeliac disease. Acta paediatrica (Oslo, Norway : 1992).Supplement. 1996;41247–48. Not sensitivity or specificity of an identified test
Martin-Villa J M, Lopez-Suarez J C, Perez-Blas M, et al. Coeliac- and enteropathy-associated autoantibodies in Spanish insulin-dependent diabetes mellitus patients and their relation to HLA antigens. Journal of Diabetes and Its Complications. 2001;15(1):38-43. Unable to extract data. [pmid: 11259925].
Martinelli P, Troncone R, Paparo F, et al. Coeliac disease and unfavourable outcome of pregnancy. Gut. 2000;46(3):332-335. Not sensitivity or specificity of an identified test. [pmid: 10673293]. [pmcid: 1727862].
Martinet Nadine, Bonnard Lionel, Regnault Veronique, et al. In vivo transglutaminase type 1 expression in normal lung, preinvasive bronchial lesions, and lung cancer. American Journal of Respiratory Cell and Molecular Biology. 2003;28(4):428-435. Not sensitivity or specificity of an identified test. [pmid: 12654631].
Martinetti M, Cuccia M, Daielli C, et al. Anti-HBV neonatal immunization with recombinant vaccine. Part II. Molecular basis of the impaired alloreactivity. Vaccine. 1995;13(6):555-560. Not sensitivity or specificity of an identified test. [pmid: 7483776].
Martinetti M, De Silvestri A, Belloni C, et al. Humoral response to recombinant hepatitis B virus vaccine at birth: role of HLA and beyond. Clinical Immunology (Orlando, Fla.). 2000;97(3):234-240. Not sensitivity or specificity of an identified test. [pmid: 11112362].
Martinez J, Chalupowicz D G, Roush R K, et al. Transglutaminase-mediated processing of fibronectin by endothelial cell monolayers. Biochemistry. 1994;33(9):2538-2545. Not sensitivity or specificity of an identified test. [pmid: 7906954].
Martinez J, Rich E, Barsigian C. Transglutaminase-mediated cross-linking of fibrinogen by human umbilical vein endothelial cells. Journal of Biological Chemistry. 1989;264(34):20502-20508. Not sensitivity or specificity of an identified test. [pmid: 2573600].
Martini S, Mengozzi G, Aimo G, et al. Diagnostic accuracies for celiac disease of four tissue transglutaminase autoantibody tests using human antigen. Clinical Chemistry. 2001;47(9):1722-1725. Improper control group. [pmid: 11514417].
Martini Silvia, Mengozzi Giulio, Aimo Giuseppe, et al. Comparative evaluation of serologic tests for celiac disease diagnosis and follow-up. Clinical Chemistry. 2002;48(6 Pt 1):960-963. Improper control group. [pmid: 12029021].
Marttinen A, Maki M. Purification of fibroblast-derived celiac disease autoantigen molecules. Pediatric Research. 1993;34(4):420-423. Not sensitivity or specificity of an identified test. [pmid: 8255670].
Marttinen A, Sulkanen S, Maki M. Human fibroblast-derived molecules as antigens in enzyme-linked immunosorbent assay for coeliac disease-specific IgA. European Journal of Clinical Investigation. 1997;27(2):135-140. Not sensitivity or specificity of an identified test. [pmid: 9061307].
Martucci S, Biagi F, Di Sabatino A, et al. Coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(Suppl 2):s150-s153. Not sensitivity or specificity of an identified test. [pmid: 12408460].
Marvin K W, George M D, Fujimoto W, et al. Cornifin, a cross-linked envelope precursor in keratinocytes that is down-regulated by retinoids. Proceedings of the National Academy of Sciences of the United States of America. 1992;89(22):11026-11030. Not sensitivity or specificity of an identified test. [pmid: 1438308]. [pmcid: 50476].
Marzari R, Sblattero D, Florian F, et al. Molecular dissection of the tissue transglutaminase autoantibody response in celiac disease. Journal of Immunology (Baltimore, Md.- 1950). 2001;166(6):4170-4176. Not sensitivity or specificity of an identified test. [pmid: 11238668].
Mascart-Lemone F. Strategy for serological screening of celiac disease. Gastroenterol Int. 1998;11(3):144-148. Not sensitivity or specificity of an identified test.
Mascart-Lemone F, Lambrechts A. Serology of coeliac disease: early diagnosis and therapeutic impact. Acta Gastro-Enterologica Belgica. 1995;58(56):388-396. Improper control group. [pmid: 8775995].
Mascart-Lemone F, Cadranel S, Delacroix D L et al. Change in molecular size of antigliadin IgA in serum related to presence of antigen in the gut. Monographs in Allergy 1988;24310–4. Not sensitivity or specificity of an identified test
Mascart-Lemone F, Cadranel S, Van den, et al. IgA immune response patterns to gliadin in serum. Int Arch Allergy Appl Immunol. 1988;86(4):412-419. Not sensitivity or specificity of an identified test. [pmid: 3261718].
Mascart-Lemone F, Van den, Broeck J, et al. Serological aspects of coeliac disease. Acta Gastro-Enterologica Belgica. 1992;55(2):200-208. Improper control group. [pmid: 1632137].
Mascart-Lemone F, Van Pachterbeek T, Duchateau J, et al. Serum IgA anti-gliadin antibodies (monomeric versus dimeric) in childhood coeliac disease. Acta Gastro-Enterologica Belgica. 1986;49(4):415-422. Not sensitivity or specificity of an identified test. [pmid: 3577611].
Masclee A A, Jansen J B, Driessen W M, et al. Gallbladder sensitivity to cholecystokinin in coeliac disease. Correlation of gallbladder contraction with plasma cholecystokinin-like immunoreactivity during infusion of cerulein. Scandinavian Journal of Gastroenterology. 1991;26(12):1279-1284. Not sensitivity or specificity of an identified test. [pmid: 1763298].
Masevitch C H, Ugolev A M, Zabelinskii E K, et al. Lumenal and membrane hydrolysis of starch in some diseases of the small intestine and pancreas. American Journal of Gastroenterology. 1975;63(4):299-306. Not sensitivity or specificity of an identified test. [pmid: 1130395].
Mason M R, Bedrossian C W, Fahey C A. Value of immunocytochemistry in the study of malignant effusions. Diagnostic Cytopathology. 1987;3(3):215-221. Not sensitivity or specificity of an identified test. [pmid: 3311665].
Masterson J B, Sweeney E C. The role of small bowel follow-through examination in the diagnosis of coeliac disease. British Journal of Radiology. 1976;49(584):660-664. Not sensitivity or specificity of an identified test. [pmid: 953384].
Mastino A, Grelli S, Piacentini M, et al. Correlation between induction of lymphocyte apoptosis and prostaglandin E2 production by macrophages infected with HIV. Cellular Immunology. 1993;152(1):120-130. Not sensitivity or specificity of an identified test. [pmid: 8242755].
Mather K J, Meddings J B, Beck P L, et al. Prevalence of IgA-antiendomysial antibody in asymptomatic low bone mineral density. American Journal of Gastroenterology. 2001;96(1):120-125. Not sensitivity or specificity of an identified test. [pmid: 11197240].
Mathus-Vliegen E M H. Lymphoma in coeliac disease. J R Soc Med. 1995;88(12):672-677. Not sensitivity or specificity of an identified test. [pmid: 8786586]. [pmcid: 1295407].
Maton P N, Selden A C, Fitzpatrick M L, et al. Defective gallbladder emptying and cholecystokinin release in celiac disease. Reversal by gluten-free diet. Gastroenterology. 1985;88(2):391-396. Not sensitivity or specificity of an identified test. [pmid: 3965328].
Matouskova E, McKay I, Povysil C, et al. Characterization of the differentiated phenotype of an organotypic model of skin derived from human keratinocytes and dried porcine dermis. Folia Biologica. 1998;44(2):59-66. Not sensitivity or specificity of an identified test. [pmid: 10730858].
Matsushita S, Nishi T, Oiso M, et al. HLA-DQ-binding peptide motifs. I. Comparative binding analysis of type II collagen-derived peptides to DR and DQ molecules of rheumatoid arthritis-susceptible and non-susceptible haplotypes. Int Immunol. 1996;8(5):757-764. Not sensitivity or specificity of an identified test. [pmid: 8671664].
Matteoni C A, Goldblum J R, Wang N, et al. Celiac disease is highly prevalent in lymphocytic colitis. Journal of Clinical Gastroenterology. 2001;32(3):225-227. Not sensitivity or specificity of an identified test. [pmid: 11246349].
Matteucci E, Cinapri V, Quilici S. Screening for coeliac disease in families of adults with Type 1 diabetes based on serological markers. Diabetes, Nutrition & Metabolism. 2001;14(1):37-42. Not sensitivity or specificity of an identified test. [pmid: 11345164].
Matysiak-Budnik T, Candalh C, Dugave C, et al. Alterations of the intestinal transport and processing of gliadin peptides in celiac disease. Gastroenterology. 2003;125(3):696-707. Not sensitivity or specificity of an identified test. [pmid: 12949716].
Maurino E C, Frisoni M, Bai J C, et al. alphainf 1-Antitrypsin clearance cannot be used to predict the severity of histological intestinal damage in adult coeliac disease. European Journal of Gastroenterology & Hepatology. 1992;4(5):373-376. Not sensitivity or specificity of an identified test.
Maurino E, Capizzano H, Niveloni S, et al. Value of endoscopic markers in celiac disease. Digestive Diseases and Sciences. 1993;38(11):2028-2033. Not sensitivity or specificity of an identified test. [pmid: 8223077].
Maurino Eduardo, Niveloni Sonia, Chernavsky Alejandra, et al. Azathioprine in refractory sprue: results from a prospective, open-label study. American Journal of Gastroenterology. 2002;97(10):2595-2602. Not sensitivity or specificity of an identified test. [pmid: 12385445].
Maury C P, Teppo A M. Demonstration of tissue 90 kD glycoprotein as antigen in circulating IgG immune complexes in dermatitis herpetiformis and coeliac disease. Lancet. 1984;2(8408):892-894. Not sensitivity or specificity of an identified test. [pmid: 6148620].
Mavromichalis J, Brueton M J, McNeish A S, et al. Evaluation of the intraepithelial lymphocyte count in the jejunum in childhood enteropathies. Gut. 1976;17(8):600-603. Not sensitivity or specificity of an identified test. [pmid: 976798]. [pmcid: 1411313].
Mawhinney H, Love A H G. Anti reticulin antibody in jejunal juice in coeliac disease. Clinical and Experimental Immunology. 1975;21(3):394-398. Not sensitivity or specificity of an identified test. [pmid: 1204254]. [pmcid: 1538310].
Mayer M, Greco L, Troncone R, et al. Compliance of adolescents with coeliac disease with a gluten free diet. Gut. 1991;32(8):881-885. Not sensitivity or specificity of an identified test. [pmid: 1885070]. [pmcid: 1378956].
Mayer M, Greco L, Troncone R, et al. Early prediction of relapse during gluten challenge in childhood celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1989;8(4):474-479. Not sensitivity or specificity of an identified test. [pmid: 2723938].
Maynard E, Ferruchi J T. Neurologic and abdominal abnormalities with the malabsorption syndrome. New Engl J Med. 1973;289(22):1186-1193. Not sensitivity or specificity of an identified test. [pmid: 4585362].
Mazzacca G. Diet, coeliac disease and gastrointestinal neoplasm. Adv Exp Med Biol. 1993;348(-):133-136. Not sensitivity or specificity of an identified test. [pmid: 8172015].
Mazzarella G, Maglio M, Paparo F, et al. An immunodominant DQ8 restricted gliadin peptide activates small intestinal immune response in in vitro cultured mucosa from HLA-DQ8 positive but not HLA-DQ8 negative coeliac patients. Gut. 2003;52(1):57-62. Not sensitivity or specificity of an identified test. [pmid: 12477760]. [pmcid: 1773526].
Mazzarella Giuseppe, MacDonald Thomas T, Salvati Virginia M, et al. Constitutive activation of the signal transducer and activator of transcription pathway in celiac disease lesions. American Journal of Pathology. 2003;162(6):1845-1855. Not sensitivity or specificity of an identified test. [pmid: 12759242]. [pmcid: 1868135].
Mazzetti di, Pietralata Giorgetti G M, Gregori M, et al. Subclinical coeliac disease. Italian Journal of Gastroenterology. 1992;24(6):352-354. Not sensitivity or specificity of an identified test. [pmid: 1515663].
Mazzilli M C, Ferrante P, Mariani P, et al. A study of Italian pediatric celiac disease patients confirms that the primary HLA association is to the DQ(alpha 1*0501, beta 1*0201) heterodimer. Human Immunology. 1992;33(2):133-139. Improper control group. [pmid: 1563982].
Mazzola G, Berrino M, Bersanti M, et al. Immunoglobulin and HLA-DP genes contribute to the susceptibility to juvenile dermatitis herpetiformis. Eur J Immunogenet. 1992;19(3):129-139. Not sensitivity or specificity of an identified test. [pmid: 1627534].
McCarthy C F. The incidence of coeliac disease and its familial occurrence. Ir Med J. 1974;67(15):420-421. Not sensitivity or specificity of an identified test. [pmid: 4374451].
McCarthy C F, Borland J L, Kurtz S M, et al. The value of the dissecting microscope in the diagnosis of nontropical sprue. American Journal of Pathology. 1964;44(4):585-595. Not sensitivity or specificity of an identified test. [pmid: 5877507].
McCarthy D M, Coleman M. Response of intestinal mucosa to gluten challenge in autistic subjects. Lancet. 1979;2(8148):877-878. Not sensitivity or specificity of an identified test. [pmid: 90968].
McCarthy D, Manning N, Rees J P R, et al. Hypothyroidism and coeliac disease. A family study. Ir J Med Sci. 1976;145(7):237-238. Not sensitivity or specificity of an identified test. [pmid: 977269].
McClean P, Dodge J A, Nunn S, et al. Surface features of small-intestinal mucosa in childhood diarrheal disorders. Journal of Pediatric Gastroenterology and Nutrition. 1996;23(5):538-546. Not sensitivity or specificity of an identified test. [pmid: 8985842].
McClelland D B, Shearman D J, Lai A, et al. In vitro synthesis of immunoglobulins, secretory component, complement and lysozyme by human gastrointestinal tissues. II. Pathological tissues. Clinical and Experimental Immunology. 1976;23(1):20-27. Not sensitivity or specificity of an identified test. [pmid: 1261087]. [pmcid: 1538366].
McCombs C C, Michalski J P. HLA and immune response. Jama - the Journal of the American Medical Association. 1989;262(6):774. Not sensitivity or specificity of an identified test. [pmid: 2526237].
McCombs C C, Leggett A, Ramsey K M, et al. The association of HLA class II alleles defined by restriction fragment length polymorphisms with responsiveness to hepatitis B vaccine. Vaccine Res. 1993;2(2):105-109. Not sensitivity or specificity of an identified test.
McCord M L, Hall R P. IgA antibodies against reticulin and endomysium in the serum and gastrointestinal secretions of patients with dermatitis herpetiformis. Dermatology. 1994;189(Suppl 1):60-63. Not sensitivity or specificity of an identified test. [pmid: 8049567].
McCormick P A, Feighery C, Dolan C, et al. Altered gastrointestinal immune response in sarcoidosis. Gut. 1988;29(12):1628-1631. Not sensitivity or specificity of an identified test. [pmid: 3265402]. [pmcid: 1434106].
McDevitt J, O'Farrelly C, Weir D G, et al. Proliferation-associated markers in the coeliac duodenum. European Journal of Gastroenterology & Hepatology. 1994;6(3):223-228. Not sensitivity or specificity of an identified test.
McElvaney N G, Duignan R, Fielding J F. Coeliac disease: clinical presentations, correlations of dietary compliance, symptomatic response and repeat biopsy findings. Ulster Medical Journal. 1992;61(2):134-138. Not sensitivity or specificity of an identified test. [pmid: 1481302].
McEwan G T, Lucas M L, Denvir M, et al. A combined TDDA-PVC pH and reference electrode for use in the upper small intestine. Journal of Medical Engineering & Technology. 1990;14(1):16-20. Not sensitivity or specificity of an identified test. [pmid: 2342080].
McGowan I, Campbell A, Jewell D P. Intestinal mucosal abnormality associated with human immunodeficiency virus infection. European Journal of Gastroenterology & Hepatology. 1994;6(9):813-819. Not sensitivity or specificity of an identified test.
McGuire E A, Davis A R, Korsmeyer S J. T-cell translocation gene 1 (Ttg-1) encodes a nuclear protein normally expressed in neural lineage cells. Blood. 1991;77(3):599-606. Not sensitivity or specificity of an identified test. [pmid: 1703797].
McIntyre A S, Long R G. Prospective survey of investigations in outpatients referred with iron deficiency anaemia. Gut. 1993;34(8):1102-1107. Not sensitivity or specificity of an identified test. [pmid: 8174963]. [pmcid: 1374363].
McIntyre A S, Ng D P, Smith J A, et al. The endoscopic appearance of duodenal folds is predictive of untreated adult celiac disease. Gastrointestinal Endoscopy. 1992;38(2):148-151. Not sensitivity or specificity of an identified test. [pmid: 1568611].
McKelvie P, Friling R, Davey K, et al. Changes as the result of ageing in extraocular muscles: A post-mortem study. Aust New Zealand J Ophthalmol. 1999;27(6):420-425. Not sensitivity or specificity of an identified test. [pmid: 10641901].
McKenna R, Stevens F M, McNicholl B, et al. Family and population studies of HLA and coeliac disease in the West of Ireland. Tissue Antigens. 1983;22(3):175-181. Not sensitivity or specificity of an identified test. [pmid: 6636110].
McManus R, Wilson A G, Mansfield J, et al. TNF2, a polymorphism of the tumour necrosis-alpha gene promoter, is a component of the celiac disease major histocompatibility complex haplotype. European Journal of Immunology. 1996;26(9):2113-2118. Not sensitivity or specificity of an identified test. [pmid: 8814255].
McManus Ross, Kelleher Dermot. Celiac disease--the villain unmasked?. New England Journal of Medicine. 2003;348(25):2573-2574. Not sensitivity or specificity of an identified test. [pmid: 12815145].
McMillan S A, Dickey W, Douglas J P, et al. Transthyretin values correlate with mucosal recovery in patients with coeliac disease taking a gluten free diet. Journal of Clinical Pathology. 2001;54(10):783-786. Not sensitivity or specificity of an identified test. [pmid: 11577127]. [pmcid: 1731281].
McMillan S A, Hutchison T, Haire M, et al. Antigliadin antibodies in dermatitis herpetiformis. Ulster Medical Journal. 1983;52(2):113-117. Not sensitivity or specificity of an identified test. [pmid: 6681090].
McMillan S A, Johnston S D, Watson R G, et al. Dietary intake, smoking, and transient anti-gliadin antibodies. Scandinavian Journal of Gastroenterology. 1998;33(5):499-503. Not sensitivity or specificity of an identified test. [pmid: 9648989].
McMillan S A, Watson R P, McCrum E E, et al. Factors associated with serum antibodies to reticulin, endomysium, and gliadin in an adult population. Gut. 1996;39(1):43-47. Not sensitivity or specificity of an identified test. [pmid: 8881807]. [pmcid: 1383229].
McNamee S, McLoughlin R, Stevens F M, et al. Coeliac disease in the older patient. Rev Clin Gerontol. 2002;12(2):119-126. Not sensitivity or specificity of an identified test.
McNeish A S. Diagnosis of coeliac disease in retrospect. Archives of Disease in Childhood. 1968;43(229):362-364. Not sensitivity or specificity of an identified test. [pmid: 5666679].
McNeish A S, Anderson C M. The disorder in childhood. Clin Gastroenterol. 1974;3(1):127-144. Not sensitivity or specificity of an identified test. [pmid: 4600388].
McNeish A S, Harms H K, Rey J, et al. The diagnosis of coeliac disease. A commentary on the current practices of members of the European Society for Paediatric Gastroenterology and Nutrition (ESPGAN). Archives of Disease in Childhood 1979. 54(10):783-786. Not sensitivity or specificity of an identified test.
McNicholl B. Coeliac disease: ecology, life history and management. Human Nutrition. Applied Nutrition. 1986;40(Suppl 1):55-60. Not sensitivity or specificity of an identified test. [pmid: 3528073].
McNicholl B, Egan B. Jejunal biopsy in celiac disease. Clinical Pediatrics. 1968;7(9):544-552. Not sensitivity or specificity of an identified test. [pmid: 5677248].
McNicholl B, Egan-Mitchell B. Infancy celiac disease without diarrhea. Pediatrics. 1972;49(1):85-91. Not sensitivity or specificity of an identified test. [pmid: 5066768].
McNicholl B, Egan Mitchell B, Fottrell P. Early diagnosis of coeliac disease. Ir Med J. 1975;68(8):187-191. Not sensitivity or specificity of an identified test. [pmid: 1132966].
McNicholl B, Egan-Mitchell B, Fottrell P F. Variability of gluten intolerance in treated childhood coeliac disease. Gut. 1979;20(2):126-132. Not sensitivity or specificity of an identified test. [pmid: 428824]. [pmcid: 1419450].
McNicholl B, Egan-Mitchell B, Stevens F, et al. Mucosal recovery in treated childhood celiac disease (gluten-sensitive enteropathy). Journal of Pediatrics. 1976;89(3):418-424. Not sensitivity or specificity of an identified test. [pmid: 956966].
McNiff J M, Glusac E J, Lazova R Z, et al. Morphea limited to the superficial reticular dermis: an underrecognized histologic phenomenon. American Journal of Dermatopathology. 1999;21(4):315-319. Not sensitivity or specificity of an identified test. [pmid: 10446770].
McPherson J R. Jejunal biopsy. Medical Clinics of North America. 1970;54(4):851-862. Not sensitivity or specificity of an identified test. [pmid: 4193250].
McPherson J R. Jejunal biopsy in the diagnosis of malabsorption syndromes. Diseases of the Colon and Rectum. 1965;8(6):425-430. Not sensitivity or specificity of an identified test. [pmid: 4158553].
McPherson R A. Commentary: advances in the laboratory diagnosis of celiac disease. Journal of Clinical Laboratory Analysis. 2001;15(3):105-107. Not sensitivity or specificity of an identified test. [pmid: 11344522].
McTernan C L, Stewart L C, Mijovic C H, et al. Assessment of the non-HLA-DR-DQ contribution to IDDM1 in British Caucasian families: Analysis of LMP7. Diabetic Med. 2000;17(9):661-666. Not sensitivity or specificity of an identified test. [pmid: 11051286].
Mearin F, Mearin M L, Pena A S. Distribution of IgA 1, and IgA 2 immunocytes in the jejunum of adult coeliac patients and controls. J Clin Nutr Gastroenterol. 1986;1(2):79-82. Not sensitivity or specificity of an identified test.
Mearin M L, Mulder C J J. Endoscopic small bowel biopsy with a guided capsule. Acta Endosc. 1994;24(4):393-401. Not sensitivity or specificity of an identified test.
Mearin M L, Pena A S. Clinical indications of HLA typing and measurement of gliadin antibodies in coeliac disease. Netherlands Journal of Medicine. 1987;31(56):279-285. Not sensitivity or specificity of an identified test. [pmid: 3323925].
Mearin M L, Biemond I, Pena A S, et al. HLA-DR phenotypes in Spanish coeliac children: their contribution to the understanding of the genetics of the disease. Gut. 1983;24(6):532-537. Not sensitivity or specificity of an identified test. [pmid: 6602084]. [pmcid: 1420005].
Mearin M L, Bouquet J, Mourad N, et al. HLA-DR antigens and phenotypes in Dutch coeliac children and their families. Clinical Genetics. 1985;27(1):45-50. Not sensitivity or specificity of an identified test. [pmid: 3872185].
Mearin M L, Koninckx C R, Biemond I, et al. Influence of genetic factors on the serum levels of antigliadin antibodies in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1984;3(3):373-377. Not sensitivity or specificity of an identified test. [pmid: 6588183].
Mearin M, Luisa Koning, Frits. Tissue transglutaminase: master regulator of celiac disease?. Journal of Pediatric Gastroenterology and Nutrition. 2003;36(1):9-11. Not sensitivity or specificity of an identified test. [pmid: 12499990].
Mecham R P, Broekelmann T, Davis E C et al. Elastic fibre assembly: macromolecular interactions. Ciba Foundation Symposium 1995;192172–181;Discussion 181–4. Not sensitivity or specificity of an identified test
Meddeb-Garnaoui A, Zeliszewski D, Mougenot J F, et al. Reevaluation of the relative risk for susceptibility to celiac disease of HLA-DRB1, -DQA1, -DQB1, -DPB1, and -TAP2 alleles in a French population. Human Immunology. 1995;43(3):190-199. Improper control group. [pmid: 7558936].
Mediene S, Hakem S, Bard J M et al. Serum lipoprotein profile in Algerian patients with celiac disease. Clinica Chimica Acta 1995;International Journal of Clinical Chemistry; 235(2):189–196. Not sensitivity or specificity of an identified test
Mehra N K, Kaur Gurvinder, Kanga Uma et al. Immunogenetics of autoimmune diseases in Asian Indians. Annals of the New York Academy of Sciences 2002;958333–336. Not sensitivity or specificity of an identified test
Mehta K. High levels of transglutaminase expression in doxorubicin-resistant human breast carcinoma cells. International Journal of Cancer. Journal International Du Cancer. 1994;58(3):400-406. Not sensitivity or specificity of an identified test. [pmid: 7914183].
Mehta K, Lopez-Berestein G. Expression of tissue transglutaminase in cultured monocytic leukemia (THP-1) cells during differentiation. Cancer Research. 1986;46(3):1388-1394. Not sensitivity or specificity of an identified test. [pmid: 2867824].
Mehta K, Lopez-Berestein G. Induction of tissue transglutaminase (TGase) in human monocytoid cells (THP-1) during retinoid and phorbol ester-induced differentation. Proc Am Assoc Cancer Res 1985;VOL. 26(-):No 164Not sensitivity or specificity of an identified test
Mehta K, Chandrashekar R, Rao U R. Transglutaminase-catalyzed incorporation of host proteins in Brugia malayi microfilariae. Mol Biochem Parasitol. 1996;76(12):105-114. Not sensitivity or specificity of an identified test. [pmid: 8919999].
Mehta K, Lopez-Berestein G, Moore W T, et al. Interferon-gamma requires serum retinoids to promote the expression of tissue transglutaminase in cultured human blood monocytes. Journal of Immunology (Baltimore, Md.- 1950). 1985;134(4):2053-2056. Not sensitivity or specificity of an identified test. [pmid: 2857744].
Mehta K, Rao U R, Vickery A C, et al. Significance of transglutaminase-catalyzed reactions in growth and development of filarial parasite, Brugia malayi. Biochem Biophys Res Commun. 1990;173(3):1051-1057. Not sensitivity or specificity of an identified test. [pmid: 1980065].
Mehta K, Rao U R, Vickery A C, et al. Identification of a novel transglutaminase from the filarial parasite Brugia malayi and its role in growth and development. Mol Biochem Parasitol. 1992;53(12):1-16. Not sensitivity or specificity of an identified test. [pmid: 1354328].
Mehta S, Wadhwa U N, Prakash A, et al. Small bowel function in severe chronic diarrhea in children. Journal of the Association of Physicians of India. 1968;16(6):342-349. Not sensitivity or specificity of an identified test. [pmid: 5714734].
Mehul B, Bernard D, Schmidt R. Calmodulin-like skin protein: a new marker of keratinocyte differentiation. Journal of Investigative Dermatology. 2001;116(6):905-909. Not sensitivity or specificity of an identified test. [pmid: 11407979].
Meijer Jos W R, Wahab Peter J, Mulder Chris J J. Small intestinal biopsies in celiac disease: duodenal or jejunal?. Virchows Archiv - an International Journal of Pathology. 2002;442(2):124-128. Improper control group. [pmid: 12596062].
Meinhard E A, Wadbrook D G, Risdon R A. Computer card morphometry of jejunal biopsies in childhood coeliac disease. Journal of Clinical Pathology. 1975;28(2):85-93. Not sensitivity or specificity of an identified test. [pmid: 1127115]. [pmcid: 475604].
Melino G, Piacentini M. ‘Tissue’ transglutaminase in cell death: a downstream or a multifunctional upstream effector?. Febs Letters. 1998;430(12):59-63. Not sensitivity or specificity of an identified test. [pmid: 9678595].
Melino G, Annicchiarico-Petruzzelli M, Piredda L, et al. Tissue transglutaminase and apoptosis: sense and antisense transfection studies with human neuroblastoma cells. Molecular and Cellular Biology. 1994;14(10):6584-6596. Not sensitivity or specificity of an identified test. [pmid: 7935379]. [pmcid: 359188].
Melino G, Catani M V, Corazzari M, et al. Nitric oxide can inhibit apoptosis or switch it into necrosis. Cellular and Molecular Life Sciences - Cmls. 2000;57(4):612-622. Not sensitivity or specificity of an identified test. [pmid: 11130461].
Melino G, Draoui M, Bellincampi L, et al. Retinoic acid receptors alpha and gamma mediate the induction of “tissue” transglutaminase activity and apoptosis in human neuroblastoma cells. Experimental Cell Research. 1997;235(1):55-61. Not sensitivity or specificity of an identified test. [pmid: 9281352].
Melino G, Farrace M G, Ceru' M P, et al. Correlation between transglutaminase activity and polyamine levels in human neuroblastoma cells. Effect of retinoic acid and alpha-difluoromethylornithine. Experimental Cell Research. 1988;179(2):429-445. Not sensitivity or specificity of an identified test. [pmid: 2903830].
Melone Mariarosa A B, Di Fede, Giuseppe Peluso, et al. Abnormal accumulation of tTGase products in muscle and erythrocytes of chorea-acanthocytosis patients. Journal of Neuropathology and Experimental Neurology. 2002;61(10):841-848. Not sensitivity or specificity of an identified test. [pmid: 12387450].
Meloni G F, Dessole S, Vargiu N, et al. The prevalence of coeliac disease in infertility. Human Reproduction (Oxford, England). 1999;14(11):2759-2761. Not sensitivity or specificity of an identified test. [pmid: 10548618].
Meloni G F, Tomasi P A, Bertoncelli A, et al. Prevalence of silent celiac disease in patients with autoimmune thyroiditis from Northern Sardinia. Journal of Endocrinological Investigation. 2001;24(5):298-302. Not sensitivity or specificity of an identified test. [pmid: 11407647].
Meloni G, Dore A, Fanciulli G, et al. Subclinical coeliac disease in schoolchildren from northern Sardinia. Lancet. 1999;353(9146):37. Not sensitivity or specificity of an identified test. [pmid: 10023953].
Menni S, Cavalli R, Prampolini R, et al. Dental enamel defects in children suffering from dermatitis herpetiformis and in their first degree relatives. Eur J Pediatr Dermatol. 1996;6(1):33-38. Not sensitivity or specificity of an identified test.
Mention Jean, Ben Ahmed, Melika Begue, et al. Interleukin 15: a key to disrupted intraepithelial lymphocyte homeostasis and lymphomagenesis in celiac disease. Gastroenterology. 2003;125(3):730-745. Not sensitivity or specificity of an identified test. [pmid: 12949719].
Menzel E J, Pehamberger H, Holubar K. Demonstration of antibodies to wheat gliadin in dermatitis herpetiformis using sup 1sup 4C-radioimmunoassay. Clin Immunol Immunopathol. 1978;10(2):193-201. Not sensitivity or specificity of an identified test. [pmid: 97037].
Menzel J. Radioimmunoassay for antigliadin-antibodies using 14C-labelled gliadin. Journal of Immunological Methods. 1977;18(34):257-268. Not sensitivity or specificity of an identified test. [pmid: 845442].
Menzies I S, Laker M F, Pounder R, et al. Abnormal intestinal permeability to sugars in villous atrophy. Lancet. 1979;2(8152):1107-1109. Not sensitivity or specificity of an identified test. [pmid: 91841].
Mercer J, Eagles M E, Talbot I C. Brush border enzymes in coeliac disease: histochemical evaluation. Journal of Clinical Pathology. 1990;43(4):307-312. Not sensitivity or specificity of an identified test. [pmid: 2187903]. [pmcid: 502361].
Merridew S R, Wilson D V, Williams E J. Antigliadin antibody measurement by chemiluminescence ELISA in the diagnosis of coeliac disease. Journal of Clinical Pathology. 1995;48(6):509-512. Improper control group. [pmid: 7665692]. [pmcid: 502678].
Merz Hartmut, Lange Karin, Gaiser Timo, et al. Characterization of a novel human anaplastic large cell lymphoma cell line tumorigenic in SCID mice. Leukemia & Lymphoma. 2002;43(1):165-172. Not sensitivity or specificity of an identified test. [pmid: 11908723].
Messing B, Dutra S L, Thuillier F, et al. Whole-body protein metabolism assessed by leucine and glutamine kinetics in adult patients with active celiac disease. Metabolism- Clinical and Experimental. 1998;47(12):1429-1433. Not sensitivity or specificity of an identified test. [pmid: 9867069].
Metha K, Turpin J, Lopez-Berestein G. Induction of tissue transglutaminase in human peripheral blood monocytes by intracellular delivery of retinoids. Journal of Leukocyte Biology. 1987;41(4):341-348. Not sensitivity or specificity of an identified test. [pmid: 2883247].
Metskula K, Grunberg H, Uibo O, et al. Antigliadin antibodies and autoantibodies among 9, 12 and 15 year-old schoolchildren. Cent-Eur J Immunol. 1998;23(34):197-202. Not sensitivity or specificity of an identified test.
Meuli R, Pichler W J, Gaze H, et al. Genetic difference in HLA-DR phenotypes between coeliac disease and transitory gluten intolerance. Archives of Disease in Childhood. 1995;72(1):29-32. Not sensitivity or specificity of an identified test. [pmid: 7717732].
Meyer B M, Campbell D R, Curington C W, et al. Bentiromide test is not affected in patients with small bowel disease or liver disease. Pancreas. 1987;2(1):44-47. Not sensitivity or specificity of an identified test. [pmid: 3494995].
Mezger J, Endo K, Walter S, et al. A pitfall in immunocytochemistry: Non-specific staining of plasmacytoid cells with immunoalkaline phosphatase techniques. J Tumor Marker Oncol. 1988;3(1):107-115. Not sensitivity or specificity of an identified test.
Mezzogiorno A, Esposito V. Potential role for high and low molecular weight tissue transglutaminases in transforming mammalian cell properties. Curr Drug Targets Immune Endocr Metabol Disord. 2001;1(3):223-232. Not sensitivity or specificity of an identified test. [pmid: 12477288].
Mian S, el Alaoui S, Lawry J, et al. The importance of the GTP-binding protein tissue transglutaminase in the regulation of cell cycle progression. Febs Letters. 1995;370(12):27-31. Not sensitivity or specificity of an identified test. [pmid: 7649299].
Mic caron, Umek-Bradac caron, Dolins caron, et al. Ultrasonographic assessment of celiac disease in children: Comparison with antiendomysium antibodies and histology. Wien Klin Wochenschr Suppl. 2001;113(3):27-31. Not sensitivity or specificity of an identified test.
Michaelsson G, Gerden B, Hagforsen E, et al. Psoriasis patients with antibodies to gliadin can be improved by a gluten-free diet. British Journal of Dermatology. 2000;142(1):44-51. Not sensitivity or specificity of an identified test. [pmid: 10651693].
Michaelsson G, Gerden B, Ottosson M, et al. Patients with psoriasis often have increased serum levels of IgA antibodies to gliadin. British Journal of Dermatology. 1993;129(6):667-673. Not sensitivity or specificity of an identified test. [pmid: 8286249].
Michaelsson G, Kraaz W, Gerden B, et al. Increased lymphocyte infiltration in duodenal mucosa from patients with psoriasis and serum IgA antibodies to gliadin. British Journal of Dermatology. 1995;133(6):896-904. Not sensitivity or specificity of an identified test. [pmid: 8547041].
Michaelsson G, Kraaz W, Gerden B, et al. Patients with psoriasis have elevated levels of serum eosinophil cationic protein and increased numbers of EG2 positive eosinophils in the duodenal stroma. British Journal of Dermatology. 1996;135(3):371-378. Not sensitivity or specificity of an identified test. [pmid: 8949428].
Michaelsson G, Kraaz W, Hagforsen E, et al. Psoriasis patients have highly increased numbers of tryptase-positive mast cells in the duodenal stroma. Br J Dermatol. 1997;136(6):866-870. Not sensitivity or specificity of an identified test. [pmid: 9217818].
Michalski J P, McCombs C C. Celiac disease: clinical features and pathogenesis. American Journal of the Medical Sciences. 1994;307(3):204-211. Not sensitivity or specificity of an identified test. [pmid: 8160711].
Michalski J P, McCombs C C, Arai T, et al. HLA-DR, DQ genotypes of celiac disease patients and healthy subjects from the West of Ireland. Tissue Antigens. 1996;47(2):127-133. Improper control group. [pmid: 8851726].
Michel S, Demarchez M. Localization and in vivo activity of epidermal transglutaminase. Journal of Investigative Dermatology. 1988;90(4):472-474. Not sensitivity or specificity of an identified test. [pmid: 2895152].
Michel S, Bernerd F, Jetten A M, et al. Expression of keratinocyte transglutamine mRNA revealed by in situ hybridization. Journal of Investigative Dermatology. 1992;98(3):364-368. Not sensitivity or specificity of an identified test. [pmid: 1347556].
Michel S, Courseaux A, Miquel C, et al. Determination of retinoid activity by an enzyme-linked immunosorbent assay. Analytical Biochemistry. 1991;192(1):232-236. Not sensitivity or specificity of an identified test. [pmid: 1675555].
Michel S, Reichert U, Isnard J L, et al. Retinoic acid controls expression of epidermal transglutaminase at the pre-translational level. Febs Letters. 1989;258(1):35-38. Not sensitivity or specificity of an identified test. [pmid: 2574114].
Michel S, Schmidt R, Robinson S M, et al. Identification and subcellular distribution of cornified envelope precursor proteins in the transformed human keratinocyte line SV-K14. Journal of Investigative Dermatology. 1987;88(3):301-305. Not sensitivity or specificity of an identified test. [pmid: 2434576].
Michelsen A E, Santi C, Holme R, et al. The charge-heterogeneity of human fibrinogen as investigated by 2D electrophoresis. Thrombosis Research. 2000;100(6):529-535. Not sensitivity or specificity of an identified test. [pmid: 11152933].
Migheli A, Mongini T, Doriguzzi C, et al. Muscle apoptosis in humans occurs in normal and denervated muscle, but not in myotonic dystrophy, dystrophinopathies or inflammatory disease. Neurogenetics. 1997;1(2):81-87. Not sensitivity or specificity of an identified test. [pmid: 10732808].
Mignot E, Kimura A, Abbal M, et al. DQCAR microsatellite polymorphisms in three selected HLA class II-associated diseases. Tissue Antigens. 1995;46(4):299-304. Not sensitivity or specificity of an identified test. [pmid: 8560448].
Miletic I D, Miletic V D, Sattely-Miller E A, et al. Identification of gliadin presence in pharmaceutical products. Journal of Pediatric Gastroenterology and Nutrition. 1994;19(1):27-33. Not sensitivity or specificity of an identified test. [pmid: 7965473].
Miletic I D, Schiffmann S S, Sattely-Miller E A, et al. Development of ELISA-based assays for detection, quantitation and avidity determination of salivary IgA anti-gliadin antibodies. Jugosl Med Biokem. 1995;14(12):15-25. Not sensitivity or specificity of an identified test.
Miller A, Paspaliaris W, Elliott P R, et al. Anti-transglutaminase antibodies and coeliac disease. Australian and New Zealand Journal of Medicine. 1999;29(2):239-242. Improper control group. [pmid: 10342024].
Miller C C, Anderton B H. Transglutaminase and the neuronal cytoskeleton in Alzheimer's disease. Journal of Neurochemistry. 1986;46(6):1912-1922. Not sensitivity or specificity of an identified test. [pmid: 2871133].
Miller M L, Johnson G V. Transglutaminase cross-linking of the tau protein. Journal of Neurochemistry. 1995;65(4):1760-1770. Not sensitivity or specificity of an identified test. [pmid: 7561874].
Milovic V, Stein J, Caspary W F. Intestinal malabsorption: Patophysiology, clinical signs and symptoms, diagnosis and treatment (First part). Arch Gastroenterohepatol. 1999;18(34):65-74. Not sensitivity or specificity of an identified test.
Ming M E, Daryanani H A, Roberts L P, et al. Binding of keratin intermediate filaments (K10) to the cornified envelope in mouse epidermis: Implicatins for barrier function. J Invest Dermatol. 1994;103(6):780-784. Not sensitivity or specificity of an identified test. [pmid: 7528240].
Mino M, Lauwers G Y. Role of lymphocytic immunophenotyping in the diagnosis of gluten-sensitive enteropathy with preserved villous architecture. Am J Surg Pathol. 2003;27(9):1237-1242. Unable to extract data. [pmid: 12960808].
Minta J O, Pambrun L. In vitro induction of cytologic and functional differentiation of the immature human monocytelike cell line U-937 with phorbol myristate acetate. American Journal of Pathology. 1985;119(1):111-126. Not sensitivity or specificity of an identified test. [pmid: 2984940]. [pmcid: 1888087].
Mirakian R, Hill S, Richardson A, et al. HLA product expression and lymphocyte subpopulations in jejunum biopsies of children with idiopathic protracted diarrhoea and enterocyte autoantibodies. Journal of Autoimmunity. 1988;1(3):263-277. Not sensitivity or specificity of an identified test. [pmid: 3266956].
Mirza A, Liu S-L, Frizell E, et al. A role for tissue transglutaminase in hepatic injury and fibrogenesis, and its regulation by NF-kappaB. Am J Physiol Gastrointest Liver Physiol. 1997;272(2 352):G281-G288. Not sensitivity or specificity of an identified test.
Misery L, Boucheron S, Claudy A L. Factor XIIIa expression in juvenile xanthogranuloma. Acta Dermato-Venereologica. 1994;74(1):43-44. Not sensitivity or specificity of an identified test. [pmid: 7511867].
Misra S, Ament M E. Diagnosis of coeliac sprue in 1994. Gastroenterology Clinics of North America. 1995;24(1):133-143. Not sensitivity or specificity of an identified test. [pmid: 7729857].
Mitchell R M S, Robinson T J. Monitoring dietary compliance in coeliac disease using red cell distribution width. International Journal of Clinical Practice. 2002;56(4):249-250. Not sensitivity or specificity of an identified test. [pmid: 12074205].
Mitchison H C, al Mardini H, Gillespie S, et al. A pilot study of fluticasone propionate in untreated coeliac disease. Gut. 1991;32(3):260-265. Not sensitivity or specificity of an identified test. [pmid: 1901562]. [pmcid: 1378830].
Mitkevich O V, Shainoff J R, DiBello P M, et al. Coagulation factor XIIIa undergoes a conformational change evoked by glutamine substrate. Studies on kinetics of inhibition and binding of XIIIA by a cross-reacting antifibrinogen antibody. Journal of Biological Chemistry. 1998;273(23):14387-14391. Not sensitivity or specificity of an identified test. [pmid: 9603949].
Mitsunaga S, Oguchi T, Tokunaga K, et al. High-resolution HLA-DQB1 typing by combination of group-specific amplification and restriction fragment length polymorphism. Hum Immunol. 1995;42(4):307-314. Not sensitivity or specificity of an identified test. [pmid: 7558915].
Mittal K K. Immunobiology of the human major histocompatibility complex: association of HLA antigens with disease. Acta Anthropogenetica. 1984;8(34):245-268. Not sensitivity or specificity of an identified test. [pmid: 6400312].
Miwa K, Doyle C, Strominger J L. Sequence-specific interactions of nuclear factors with conserved sequences of human class II major histocompatibility complex genes. Proc Natl Acad Sci U S A. 1987;84(14):4939-4943. Not sensitivity or specificity of an identified test. [pmid: 3037529]. [pmcid: 305222].
Miyagawa S, Shinohara K, Fujita T, et al. Neonatal lupus erythematosus: Analysis of HLA class II alleles in mothers and siblings from seven Japanese families. J Am Acad Dermatol. 1997;36(2):186-190. Not sensitivity or specificity of an identified test. [pmid: 9039166].
Mizugami T, Mikata A, Hajikano H, et al. Childhood lymphoma. A clinicopathological and immunohistological study of 58 cases. Acta Pathologica Japonica. 1988;38(9):1149-1166. Not sensitivity or specificity of an identified test. [pmid: 3071939].
Moayyedi P, O'Mahony S, Jackson P, et al. Small intestine in lymphocytic and collagenous colitis: mucosal morphology, permeability, and secretory immunity to gliadin. Journal of Clinical Pathology. 1997;50(6):527-529. Not sensitivity or specificity of an identified test. [pmid: 9378824]. [pmcid: 500002].
Mobacken H, Andersson H, Dahlberg E, et al. Relationship of dietary gluten intake to dapsone dose in dermatitis herpetiformis. Acta Dermato-Venereologica. 1987;67(3):267-270. Not sensitivity or specificity of an identified test. [pmid: 2442946].
Mobacken H, Kastrup W, Ljunghall K. Linear IgA dermatosis: A study of ten adult patients. Acta Derm-Venereol. 1983;63(2):123-128. Not sensitivity or specificity of an identified test. [pmid: 6189326].
Modigliani R, Poitras P, Galian A. Chronic non-specific ulcerative duodenojejunoileitis: Report of four cases. Gut. 1979;20(4):318-328. Not sensitivity or specificity of an identified test. [pmid: 447113]. [pmcid: 1412403].
Mohan K, Pinto D, Issekutz T B. Identification of tissue transglutaminase as a novel molecule involved in human CD8SUP+ T cell transendothelial migration. J Immunol. 2003;171(6):3179-3186. Not sensitivity or specificity of an identified test. [pmid: 12960346].
Mohindra S, Yachha S K, Srivastava A, et al. Coeliac disease in Indian children: assessment of clinical, nutritional and pathologic characteristics. Journal of Health, Population, and Nutrition. 2001;19(3):204-208. Not sensitivity or specificity of an identified test. [pmid: 11761775].
Mokhallalaty M, Debek A, Naja Z, et al. Celiac disease at Makassed General Hospital (8 years of experience). Rev Med Liban. 2002;14(23):49-53. Not sensitivity or specificity of an identified test.
Molberg O, Kett K, Scott H, et al. Gliadin specific, HLA DQ2-restricted T cells are commonly found in small intestinal biopsies from coeliac disease patients, but not from controls. Scandinavian Journal of Immunology. 1997;46(1):103-108. Not sensitivity or specificity of an identified test. [pmid: 9315123].
Molberg O, Lundin K E, Nilsen E M, et al. HLA restriction patterns of gliadin- and astrovirus-specific CD4+ T cells isolated in parallel from the small intestine of celiac disease patients. Tissue Antigens. 1998;52(5):407-415. Not sensitivity or specificity of an identified test. [pmid: 9864029].
Molberg O, McAdam S N, Sollid L M. Role of tissue transglutaminase in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 2000;30(3):232-240. Not sensitivity or specificity of an identified test. [pmid: 10749404].
Molberg O, McAdam S N, Korner R, et al. Tissue transglutaminase selectively modifies gliadin peptides that are recognized by gut-derived T cells in celiac disease. Nature Medicine. 1998;4(6):713-717. Not sensitivity or specificity of an identified test. [pmid: 9623982].
Molberg O, McAdam S, Lundin K E, et al. T cells from celiac disease lesions recognize gliadin epitopes deamidated in situ by endogenous tissue transglutaminase. European Journal of Immunology. 2001;31(5):1317-1323. Not sensitivity or specificity of an identified test. [pmid: 11465088].
Molberg Oyvind, Solheim Flaete, Nina Jensen, et al. Intestinal T-cell responses to high-molecular-weight glutenins in celiac disease. Gastroenterology. 2003;125(2):337-344. Not sensitivity or specificity of an identified test. [pmid: 12891534].
Monaghan P, Clarke C L, Perusinghe N P, et al. Epidermal growth factor receptor expression on human breast luminal and basal cells in vitro. Epithelial Cell Biology. 1995;4(2):52-62. Not sensitivity or specificity of an identified test. [pmid: 8688918].
Monos D S, Czanky E, Ono S J, et al. L cells expressing DQ molecules of the DR3 and DR4 haplotypes: reactivity patterns with mAbs. Immunogenetics. 1995;42(3):172-180. Not sensitivity or specificity of an identified test. [pmid: 7642228].
Monsonego A, Friedmann I, Shani Y, et al. GTP-dependent conformational changes associated with the functional switch between Galpha and cross-linking activities in brain-derived tissue transglutaminase. Journal of Molecular Biology. 1998;282(4):713-720. Not sensitivity or specificity of an identified test. [pmid: 9743620].
Montalto M, Cuoco L, Ricci R, et al. Immunohistochemical analysis of ZO-1 in the duodenal mucosa of patients with untreated and treated celiac disease. Digestion. 2002;65(4):227-233. Not sensitivity or specificity of an identified test. [pmid: 12239464].
Monteiro E, Menezes M L, Magalhaes Ramalho P. Anti-reticulin antibodies: a diagnostic and monitoring test for childhood coeliac disease. Scandinavian Journal of Gastroenterology. 1986;21(8):955-957. Not sensitivity or specificity of an identified test. [pmid: 3535013].
Monteiro M R, Shapiro S S, Takafuta T, et al. Von Willebrand factor receptor GPIb alpha is expressed by human factor XIIIa-positive dermal dendrocytest and is upregulated by mast cell degranulation. Journal of Investigative Dermatology. 1999;113(2):272-276. Not sensitivity or specificity of an identified test. [pmid: 10469316].
Monteleone G, Pender S L F, Alstead E, et al. Role of interferon alpha in promoting T helper cell type 1 responses in the small intesttine in coeliac disease. Gut. 2001;48(3):425-429. Not sensitivity or specificity of an identified test. [pmid: 11171837]. [pmcid: 1760133].
Monteleone G, Pender S L, Wathen N C. Interferon-alpha drives T cell-mediated immunopathology in the intestine. European Journal of Immunology. 2001;31(8):2247-2255. Not sensitivity or specificity of an identified test. [pmid: 11477536].
Montgomery A M P, Goka A K J, Kumar P J, et al. Low gluten diet in the treatment of adult coeliac disease: Effect on jejunal morphology and serum anti-gluten antibodies. Gut. 1988;29(11):1564-1568. Serology <1990. [pmid: 3209114]. [pmcid: 1433820].
Montgomery R D, Atiyeh M, Scales W R, et al. Intestinal absorption in Saudi Arabia: an evaluation of the one hour blood xylose test. Transactions of the Royal Society of Tropical Medicine and Hygiene. 1982;76(1):25-28. Not sensitivity or specificity of an identified test. [pmid: 7080153].
Moodie S, Ciclitira P. Coeliac disease: Genetic factors and antigen presentation: MALADIE CoeLIAQUE: FACTEURS GENETIQUES ET PRESENTATION DES ANTIGENES. Acta Endosc. 2001;31(3):255-264. Not sensitivity or specificity of an identified test.
Moodie S J, Ciclitira P. Recent developments in celiac disease. Curr Opin Gastroenterol. 2002;18(2):182-186. Not sensitivity or specificity of an identified test. [pmid: 17033284].
Moodie S J, Norman P J, King A L, et al. Analysis of candidate genes on chromosome 19 in coeliac disease: an association study of the KIR and LILR gene clusters. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 2002;29(4):287-291. Not sensitivity or specificity of an identified test. [pmid: 12121272].
Moore K G, Goulet F, Sartorelli A C. Purification of annexin I and annexin II from human placental membranes by high-performance liquid chromatography. Protein Expression and Purification. 1992;3(1):1-7. Not sensitivity or specificity of an identified test. [pmid: 1422205].
Moore R H, Hitman G A, Medcraft J, et al. HLA-DP region gene polymorphism in primary IgA nephropathy: no association. Nephrol Dial Transplant. 1992;7(3):200-204. Not sensitivity or specificity of an identified test. [pmid: 1314989].
Mora Barbara, Bonamico Margherita, Indovina Paola, et al. CTLA-4 +49 A/G dimorphism in Italian patients with celiac disease. Human Immunology. 2003;64(2):297-301. Not sensitivity or specificity of an identified test. [pmid: 12559633].
Mora S, Barera G, Beccio S, et al. A prospective, longitudinal study of the long-term effect of treatment on bone density in children with celiac disease. Journal of Pediatrics. 2001;139(4):516-521. Not sensitivity or specificity of an identified test. [pmid: 11598597].
Morales M, Galvan E, Mery C M, et al. Exocrine pancreatic insufficiency in tropical sprue. Digestion. 2001;63(1):30-34. Not sensitivity or specificity of an identified test. [pmid: 11173897].
Mordenti C, Peris K, Concetta Fargnoli M, et al. Cutaneous metastatic breast carcinoma: A study of 164 patients. Acta Dermatovenerol Alp Panonica Adriat. 2000;9(4):143-148. Not sensitivity or specificity of an identified test.
Morellini M, Trabace S, Mazzilli M C, et al. A study of HLA class II antigens in an Italian paediatric population with coeliac disease. Disease Markers. 1988;6(1):23-28. Not sensitivity or specificity of an identified test. [pmid: 3396269].
Moretto J C, Soslow R A, Smoller B R. Atypical cells in radiation dermatitis express factor XIIIa. American Journal of Dermatopathology. 1998;20(4):370-372. Not sensitivity or specificity of an identified test. [pmid: 9700375].
Morin C L, Roy C C, Lasalle R, et al. Small bowel mucosal dysfunction in patients with cystic fibrosis. Journal of Pediatrics. 1976;88(2):213-216. Not sensitivity or specificity of an identified test. [pmid: 1249682].
Morris M A, Ciclitira P J. Coeliac disease. Journal of the Royal College of Physicians of London. 1997;31(6):614-618. Not sensitivity or specificity of an identified test. [pmid: 9409492].
Morris M A, Yiannakou J Y, King A L, et al. Coeliac disease and Down syndrome: associations not due to genetic linkage on chromosome 21. Scandinavian Journal of Gastroenterology. 2000;35(2):177-180. Not sensitivity or specificity of an identified test. [pmid: 10720116].
Morris M-A, Ciclitira P J. Celiac disease. Curr Opin Gastroenterol. 1998;14(2):107-111. Not sensitivity or specificity of an identified test.
Morris S J, Rogers A I. Diarrhea after gastrectomy and vagotomy. Postgraduate Medicine 1979;65(1):219–22, 225. Not sensitivity or specificity of an identified test
Morroni M, Sbarbati A, D'Angelo G, et al. Scanning electron microscopy of the small intestine mucosa in children with celiac disease after long-term dietary treatment. Scanning Microscopy. 1989;3(4):1161-1166. Not sensitivity or specificity of an identified test. [pmid: 2633334].
Mortimer P E, Stewart J S, Norman A P, et al. Follow-up study of coeliac disease. British Medical Journal. 1968;3(609):7-9. Not sensitivity or specificity of an identified test. [pmid: 5661931]. [pmcid: 1989483].
Mosher D F. Action of fibrin stabilizing factor on cold insoluble globulin and alphainf 2 macroglobulin in clotting plasma. J Biol Chem. 1976;251(6):1639-1645. Not sensitivity or specificity of an identified test. [pmid: 56335].
Mosher D F, Johnson R B. In vitro formation of disulfide-bonded fibronectin multimers. Journal of Biological Chemistry. 1983;258(10):6595-6601. Not sensitivity or specificity of an identified test. [pmid: 6133865].
Mosnier J F, Larvol L, Barge J, et al. Lymphocytic and collagenous colitis: an immunohistochemical study. American Journal of Gastroenterology. 1996;91(4):709-713. Not sensitivity or specificity of an identified test. [pmid: 8677934].
Moss S F, Attia L, Scholes J V, et al. Increased small intestinal apoptosis in coeliac disease. Gut. 1996;39(96):811-817. Not sensitivity or specificity of an identified test. [pmid: 9038662]. [pmcid: 1383452].
Moustakas A K, van de, Wal Y, et al. Structure of celiac disease-associated HLA-DQ8 and non-associated HLA-DQ9 alleles in complex with two disease-specific epitopes. Int Immunol. 2000;12(8):1157-1166. Not sensitivity or specificity of an identified test. [pmid: 10917890].
Mowat A M. Dietary modifications: food dependent autoimmunity in coeliac disease. Gut. 1998;43(5):599-600. Not sensitivity or specificity of an identified test. [pmid: 9824335]. [pmcid: 1727299].
Mowat A M. Coeliac disease - A future for peptide therapy?. Lancet. 2000;356(9226):270-271. Not sensitivity or specificity of an identified test. [pmid: 11071179].
Mowat Allan, McI. Coeliac disease--a meeting point for genetics, immunology, and protein chemistry. Lancet. 2003;361(9365):1290-1292. Not sensitivity or specificity of an identified test. [pmid: 12699968].
Moyana T N, Shukoor S. Gastrointestinal endocrine cell hyperplasia in celiac disease: a selective proliferative process of serotonergic cells. Modern Pathology - an Official Journal of the United Statest and Canadian Academy of Pathology, Inc. 1991;4(4):419-423. Not sensitivity or specificity of an identified test.
Muers M F, Faux J A, Ting A, et al. HLA-A, B, C and HLA-DR antigens in extrinsic allergic alveolitis (budgerigar fancier's lung disease). Clinical Allergy. 1982;12(1):47-53. Not sensitivity or specificity of an identified test. [pmid: 7067067].
Mugica F, Castiella A, Otazua P, et al. Prevalence of coeliac disease in unexplained chronic hypertransaminasemia. Revista Espanola De Enfermedades Digestivas - Organo Oficial De La Sociedad Espanola De Patologia Digestiva. 2001;93(11):707-714. Not sensitivity or specificity of an identified test. [pmid: 11995370].
Mulder C J J. Do we have to screen the general population for coeliac disease instead of only patients with so-called associated diseases?. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2000;32(9):780-781. Not sensitivity or specificity of an identified test. [pmid: 11215558].
Mulder C J, van Bergeijk J D, Jansen T L et al. Coeliac disease. Diagnostic and therapeutic pitfalls. Scandinavian Journal of Gastroenterology.Supplement 1993;20042–47. Not sensitivity or specificity of an identified test
Mulder C J, Wahab P J, Meijer J W, et al. A pilot study of recombinant human interleukin-10 in adults with refractory coeliac disease. European Journal of Gastroenterology & Hepatology. 2001;13(10):1183-1188. Not sensitivity or specificity of an identified test. [pmid: 11711774].
Mulder C J, Wahab P J, Moshaver B et al. Refractory coeliac disease: a window between coeliac disease and enteropathy associated T cell lymphoma. Scandinavian Journal of Gastroenterology.Supplement 2000;(232):32–37. Not sensitivity or specificity of an identified test
Muller W F. Enteroclysis in coeliac disease. Radiologia Clinica. 1976;45(24):140-154. Not sensitivity or specificity of an identified test. [pmid: 968037].
Murch S H. Unusual enteropathies. Gastrointestinal Endoscopy Clinics of North America 2001;11(4): 741–66, Vii. Not sensitivity or specificity of an identified test
Murdock P J, Owens D L, Chitolie A, et al. Development and evaluation of ELISAs for factor XIIIA and XIIIB subunits in plasma. Thrombosis Research. 1992;67(1):73-79. Not sensitivity or specificity of an identified test. [pmid: 1359667].
Murphy M S, Sood M, Johnson T. Use of the lactose HSUB2 breath testt to monitor mucosal healing in coeliac disease. Acta Paediatr Int J Paediatr. 2002;91(2):141-144. Not sensitivity or specificity of an identified test.
Murray I A, Bullimore D W, Long R G. Fasting plasma nitric oxide products in coeliac disease. European Journal of Gastroenterology & Hepatology. 2003;15(10):1091-1095. Not sensitivity or specificity of an identified test. [pmid: 14501617].
Murray I A, Coupland K, Smith J A, et al. Intestinal trehalase activity in a UK population: establishing a normal range and the effect of disease. British Journal of Nutrition. 2000;83(3):241-245. Not sensitivity or specificity of an identified test. [pmid: 10884712].
Murray I A, Smith J A, Coupland K, et al. Intestinal disaccharidase deficiency without villous atrophy may represent early celiac disease. Scandinavian Journal of Gastroenterology. 2001;36(2):163-168. Not sensitivity or specificity of an identified test. [pmid: 11252408].
Murray Iain A, Daniels Ian, Coupland Kathryn, et al. Increased activity and expression of iNOS in human duodenal enterocytes from patients with celiac disease. American Journal of Physiology. Gastrointestinal and Liver Physiology. 2002;283(2):G319-G326. Not sensitivity or specificity of an identified test. [pmid: 12121878].
Murray J A. It's not time to put away the biopsy forceps. American Journal of Gastroenterology. 1999;94(4):869-871. Review article. [pmid: 10201447].
Murray J A. The widening spectrum of celiac disease. American Journal of Clinical Nutrition. 1999;69(3):354-365. Not sensitivity or specificity of an identified test. [pmid: 10075317].
Murray J A. Serodiagnosis of celiac disease. Clin Lab Med. 1997;17(3):445-464. Not sensitivity or specificity of an identified test. [pmid: 9316768].
Murray J A, Herlein J, Mitros F, et al. Serologic testting for celiac disease in the United Statest: Results of a multilaboratory comparison study. Clin Diagn Lab Immunol. 2000;7(4):584-587. Unable to extract data. [pmid: 10882656]. [pmcid: 95918].
Murtaugh M P, Arend W P, Davies P J. Induction of tissue transglutaminase in human peripheral blood monocytes. Journal of Experimental Medicine. 1984;159(1):114-125. Not sensitivity or specificity of an identified test. [pmid: 6141210].
Murtaugh M P, Mehta K, Johnson J, et al. Induction of tissue transglutaminase in mouse peritoneal macrophages. Journal of Biological Chemistry. 1983;258(18):11074-11081. Not sensitivity or specificity of an identified test. [pmid: 6136512].
Murthy S N, Lorand L. Cross-linked A alpha gamma chain hybrids serve as unique markers for fibrinogen polymerized by tissue transglutaminase. Proceedings of the National Academy of Sciences of the United States of America 1990. 1990;87(24):9679-9682. Not sensitivity or specificity of an identified test.
Murthy S N P, Iismaa Siiri, Begg Gillian, et al. Conserved tryptophan in the core domain of transglutaminase is essential for catalytic activity. Proceedings of the National Academy of Sciences of the United Statest of America. 2002;99(5):2738-2742. Not sensitivity or specificity of an identified test.
Murthy S N, Wilson J H, Lukas T J, et al. Cross-linking sitest of the human tau protein, probed by reactions with human transglutaminase. Journal of Neurochemistry. 1998;71(6):2607-2614. Not sensitivity or specificity of an identified test. [pmid: 9832162].
Murthy S N, Wilson J, Guy S L, et al. Intramolecular crosslinking of monomeric fibrinogen by tissue transglutaminase. Proceedings of the National Academy of Sciences of the United Statest of America. 1991;88(23):10601-10604. Not sensitivity or specificity of an identified test.
Murthy S N, Wilson J, Zhang Y, et al. Residue Gln-30 of human erythrocyte anion transporter is a prime site for reaction with intrinsic transglutaminase. Journal of Biological Chemistry. 1994;269(36):22907-22911. Not sensitivity or specificity of an identified test. [pmid: 7915720].
Mussche M, Thienpont L. Adult celiac disease complicated by intestinal reticulum cell sarcoma with high serum IgA level. Acta Clinica Belgica. 1974;29(6):388-393. Not sensitivity or specificity of an identified test. [pmid: 4613099].
Mustafa A S, Shaban F A, Al Attiyah R, et al. Human Th1 cell lines recognize the Mycobacterium tuberculosis ESAT-6 antigen and its peptides in association with frequently expressed HLA class II molecules. Scand J Immunol. 2003;57(2):125-134. Not sensitivity or specificity of an identified test. [pmid: 12588658].
Mustajoki P, Vuoristo M, Reunala T. Celiac disease or dermatitis herpetiformis in three patients with porphyria. Digestive Diseases and Sciences. 1981;26(7):618-621. Not sensitivity or specificity of an identified test. [pmid: 7249897].
Mustalahti K, Holopainen P, Karell K, et al. Genetic dissection between silent and clinically diagnosed symptomatic forms of coeliac disease in multiplex families. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(12):842-845. Improper control group. [pmid: 12643291].
Mustalahti K, Sulkanen S, Holopainen P, et al. Coeliac disease among healthy members of multiple case coeliac disease families. Scandinavian Journal of Gastroenterology. 2002;37(2):161-165. Not sensitivity or specificity of an identified test. [pmid: 11843051].
Mustalahti Kirsi, Lohiniemi Susanna, Collin Pekka, et al. Gluten-free diet and quality of life in patients with screen-detected celiac disease. Effective Clinical Practice - Ecp. 2002;5(3):105-113. Not sensitivity or specificity of an identified test. [pmid: 12088289].
Muszbek L, Adany R, Kavai M, et al. Monocytest of patients congenitally deficient in plasma factor XIII lack factor XIII subunit a antigen and transglutaminase activity. Thrombosis and Haemostasis. 1988;59(2):231-235. Not sensitivity or specificity of an identified test. [pmid: 2898817].
Muszbek L, Adany R, Szegedi G, et al. Factor XIII of blood coagulation in human monocytes. Thrombosis Research. 1985;37(3):401-410. Not sensitivity or specificity of an identified test. [pmid: 2859670].
Myhre A G, Aarsetoy H, Undlien D E, et al. High frequency of coeliac disease among patients with autoimmune adrenocortical failure. Scandinavian Journal of Gastroenterology. 2003;38(5):511-515. Not sensitivity or specificity of an identified test. [pmid: 12795461].
Myhre Anne, Grethe Undlien, Dag E, et al. Autoimmune adrenocortical failure in Norway autoantibodies and human leukocyte antigen class II associations related to clinical features. Journal of Clinical Endocrinology and Metabolism. 2002;87(2):618-623. Not sensitivity or specificity of an identified test. [pmid: 11836294].
Mylotte M, Egan-Mitchell B, Fottrell P F, et al. Family studies in coeliac disease. Quarterly Journal of Medicine. 1974;43(171):359-369. Not sensitivity or specificity of an identified test. [pmid: 4421975].
Mylotte M, Egan-Mitchell B, McCarthy C F, et al. Incidence of coeliac disease in the West of Ireland. British Medical Journal. 1973;1(5855):703-705. Not sensitivity or specificity of an identified test. [pmid: 4726162]. [pmcid: 1588876].
Myoung Hee, Park Dong, Hee Whang, et al. High resolution HLA-DQB1 typing by combination of PCR-RFLP and PCR-SSCP. Hum Immunol. 1999;60(9):901-907. Not sensitivity or specificity of an identified test. [pmid: 10527400].
Naccarato R, Di Mario F. Italian gastroenterology: Eyes on the new millennium. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2000;32(1):3-8. Not sensitivity or specificity of an identified test. [pmid: 10975747].
Nagae S, Lichti U, De Luca L M, et al. Effect of retinoic acid on cornified envelope formation: Difference between spontaneous envelope formation in vivo or in vitro and expression of envelope competence. J Invest Dermatol. 1987;89(1):51-58. Not sensitivity or specificity of an identified test. [pmid: 2885378].
Nagasaka T, Nakamura S, Medeiros J, et al. Anaplastic large cell lymphomas presented as bone lesions: A clinicopathologic study of six cases and review of the literature. Mod Pathol. 2000;13(10):1143-1149. Not sensitivity or specificity of an identified test. [pmid: 11048810].
Nagy L, Saydak M, Shipley N, et al. Identification and characterization of a versatile retinoid response element (retinoic acid receptor response element-retinoid X receptor response element) in the mouse tissue transglutaminase gene promoter. Journal of Biological Chemistry. 1996;271(8):4355-4365. Not sensitivity or specificity of an identified test. [pmid: 8626785].
Nagy L, Thomazy V A, Chandraratna R A, et al. Retinoid-regulated expression of BCL-2 and tissue transglutaminase during the differentiation and apoptosis of human myeloid leukemia (HL-60) cells. Leukemia Research. 1996;20(6):499-505. Not sensitivity or specificity of an identified test. [pmid: 8709622].
Naik S. HLA and gastrointestinal disorders. Indian Journal of Gastroenterology - Official Journal of the Indian Society of Gastroenterology. 1986;5(2):121-124. Not sensitivity or specificity of an identified test. [pmid: 3781584].
Naim H Y. Secretion of human intestinal angiotensin-converting enzyme and its association with the differentiation state of intestinal cells. Biochemical Journal. 1996;316(Pt 1):259-264. Not sensitivity or specificity of an identified test. [pmid: 8645215]. [pmcid: 1217332].
Nakachi K, Swift G, Wilmot D et al. Antibodies to tissue transglutaminase: comparison of ELISA and immunoprecipitation assay in the presence and in the absence of calcium ions. Clinica Chimica Acta 2001;International Journal of Clinical Chemistry; 304(1–2):75–84. Not sensitivity or specificity of an identified test
Nakamura T, Nishida K, Dota A, et al. Elevated expression of transglutaminase 1 and keratinization-related proteins in conjunctiva in severe ocular surface disease. Investigative Ophthalmology & Visual Science. 2001;42(3):549-556. Not sensitivity or specificity of an identified test. [pmid: 11222510].
Nakane H, Ishida-Yamamoto A, Takahashi H, et al. Elafin, a secretory protein, is cross-linked into the cornified cell envelopes from the inside of psoriatic keratinocytes. J Invest Dermatol. 2002;119(1):50-55. Not sensitivity or specificity of an identified test. [pmid: 12164924].
Nakshabendi I M, Downie S, Russell R I, et al. Increased ratest of duodenal mucosal protein synthesis in vivo in patients with untreated coelia disease. Gut. 1996;39(2):176-179. Not sensitivity or specificity of an identified test. [pmid: 8991854]. [pmcid: 1383294].
Naluai A T, Nilsson S, Samuelsson L, et al. The CTLA4/CD28 gene region on chromosome 2q33 confers susceptibility to celiac disease in a way possibly distinct from that of type 1 diabetes and other chronic inflammatory disorders. Tissue Antigens. 2000;56(4):350-355. Not sensitivity or specificity of an identified test. [pmid: 11098935].
Nanda A, Al Saeed K, Dvorak R, et al. Clinicopathological features and HLA tissue typing in pemphigoid gestationis patients in Kuwait. Clin Exp Dermatol. 2003;28(3):301-306. Not sensitivity or specificity of an identified test. [pmid: 12780719].
Nara K, Ito S, Ito T, et al. Elastase inhibitor elafin is a new type of proteinase inhibitor which has a transglutaminase-mediated anchoring sequence termed “cementoin”. Journal of Biochemistry. 1994;115(3):441-448. Not sensitivity or specificity of an identified test. [pmid: 7914520].
Nardacci Roberta, Lo Iacono, Oreste Ciccosanti, et al. Transglutaminase type II plays a protective role in hepatic injury. American Journal of Pathology. 2003;162(4):1293-1303. Not sensitivity or specificity of an identified test. [pmid: 12651621]. [pmcid: 1851212].
Natah S S, Hayrinen-Immonen R, Hietanen J, et al. Factor XIIIa-positive dendrocytest are increased in number and size in recurrent aphthous ulcers (RAU). Journal of Oral Pathology & Medicine - Official Publication of the International Association of Oral Pathologists and the American Academy of Oral Pathology. 1997;26(9):408-413. Not sensitivity or specificity of an identified test. [pmid: 9385578].
Nathavitharana K A, Lloyd D R, Raafat F, et al. Urinary mannitol: lactulose excretion ratios and jejunal mucosal structure. Archives of Disease in Childhood. 1988;63(9):1054-1059. Not sensitivity or specificity of an identified test. [pmid: 3140738].
Natter S, Granditsch G, Reichel G L, et al. IgA cross-reactivity between a nuclear autoantigen and wheat proteins suggests molecular mimicry as a possible pathomechanism in celiac disease. European Journal of Immunology. 2001;31(3):918-928. Not sensitivity or specificity of an identified test. [pmid: 11241297].
Negi M, Colbert M C, Goldsmith L A. High-molecular-weight human epidermal transglutaminase. Journal of Investigative Dermatology. 1985;85(1):75-78. Not sensitivity or specificity of an identified test. [pmid: 2861239].
Nehra V. New clinical issues in celiac disease. Gastroenterology Clinics of North America. 1998;27(2):453-465. Not sensitivity or specificity of an identified test. [pmid: 9650027].
Nehra V, Angulo P, Buchman A L, et al. Nutritional and metabolic considerations in the etiology of nonalcoholic steatohepatitis. Digestive Diseases and Sciences. 2001;46(11):2347-2352. Not sensitivity or specificity of an identified test. [pmid: 11713934].
Nelsen David A. Gluten-sensitive enteropathy (celiac disease): more common than you think. American Family Physician. 2002;66(12):2259-2266. Not sensitivity or specificity of an identified test. [pmid: 12507163].
Nelson E W, Ertan A, Brooks F P, et al. Thrombocytosis in patients with celiac sprue. Gastroenterology. 1976;70(6):1042-1044. Not sensitivity or specificity of an identified test. [pmid: 1269862].
Nelson R, McNeish A S, Anderson C M. Coeliac disease in children of Asian immigrants. Lancet. 1973;1(7799):348-350. Not sensitivity or specificity of an identified test. [pmid: 4121938].
Nemes Z, Thomazy V. Diagnostic significance of histiocyte-related markers in malignant histiocytosis and true histiocytic lymphoma. Cancer. 1988;62(9):1970-1980. Not sensitivity or specificity of an identified test. [pmid: 2901905].
Nemes Z, Adany R, Thomazy V. Selective visualization of human dendritic reticulum cells in reactive lymphoid follicles by the immunohistochemical demonstration of the subunit A of factor XIII (F-XIIIa). Virchows Archiv B, Cell Pathology Including Molecular Pathology. 1987;52(5):453-466. Not sensitivity or specificity of an identified test. [pmid: 2883767].
Nemes Z, Adany R, Balazs M, et al. Identification of cytoplasmic actin as an abundant glutaminyl substrate for tissue transglutaminase in HL-60 and U937 cells undergoing apoptosis. Journal of Biological Chemistry. 1997;272(33):20577-20583. Not sensitivity or specificity of an identified test. [pmid: 9252372].
Nemes Z, Thomazy V, Adany R, et al. Identification of histiocytic reticulum cells by the immunohistochemical demonstration of factor XIII (F-XIIIa) in human lymph nodes. Journal of Pathology. 1986;149(2):121-132. Not sensitivity or specificity of an identified test. [pmid: 2874201].
Nepom G T. MHC genes in HLA-associated disease. Current Opinion in Immunology. 1989;2(4):588-592. Not sensitivity or specificity of an identified test. [pmid: 2700901].
Nepom G T. Structural variation among major histocompatibility complex class-II genes which predispose to autoimmunity. Immunol Res. 1989;8(1):16-38. Not sensitivity or specificity of an identified test. [pmid: 2494275].
Nepom G T, Erlich H. MHC class-II molecules and autoimmunity. Annu Rev Immunol 1991;9493–525. Not sensitivity or specificity of an identified test
Nestle F O, Zheng X G, Thompson C B, et al. Characterization of dermal dendritic cells obtained from normal human skin reveals phenotypic and functionally distinctive subsets. Journal of Immunology (Baltimore, Md.- 1950). 1993;151(11):6535-6545. Not sensitivity or specificity of an identified test. [pmid: 7504023].
Neuberger J. PBC and the gut: the villi atrophy, the plot thickens. Gut. 1999;44(5):594-595. Not sensitivity or specificity of an identified test. [pmid: 10485854]. [pmcid: 1727492].
Neuhausen Susan L, Feolo Mike, Camp Nicola J, et al. Genome-wide linkage analysis for celiac disease in North American families. American Journal of Medical Genetics. 2002;111(1):1-9. Not sensitivity or specificity of an identified test. [pmid: 12124726].
Neuhausen Susan L, Weizman Zvi, Camp Nicola J, et al. HLA DQA1-DQB1 genotypes in Bedouin families with celiac disease. Human Immunology. 2002;63(6):502-507. Improper control group. [pmid: 12039527].
Nezelof C, Barbey S, Gogusev J, et al. Malignant histiocytosis in childhood: a distinctive CD30-positive clinicopathological entity associated with a chromosomal translocation involving 5q35. Seminars in Diagnostic Pathology. 1992;9(1):75-89. Not sensitivity or specificity of an identified test. [pmid: 1313990].
Nicholas D S, Harris S, Wright D H. Lymphocyte predominance Hodgkin's disease--an immunohistochemical study. Histopathology. 1990;16(2):157-165. Not sensitivity or specificity of an identified test. [pmid: 2323737].
Nicholl R M, Gamsu H R. Reduced mesenteric blood flow velocity in ‘AGA’ VLBW babies with disproportionate growth retardation. Early Hum Dev. 1997;49(3):209-210. Not sensitivity or specificity of an identified test.
Nickoloff B J, Griffiths C E. The spindle-shaped cells in cutaneous Kaposi's sarcoma. Histologic simulators include factor XIIIa dermal dendrocytes. American Journal of Pathology. 1989;135(5):793-800. Not sensitivity or specificity of an identified test. [pmid: 2574536]. [pmcid: 1880095].
Nicolas M E O, Krause P K, Gibson L E, et al. Dermatitis herpetiformis. International Journal of Dermatology. 2003;42(8):588-600. Not sensitivity or specificity of an identified test. [pmid: 12890100].
Nicolette C C, Tully T E. The duodenum in celiac sprue. American Journal of Roentgenology, Radium Therapy, and Nuclear Medicine. 1971;113(2):248-254. Not sensitivity or specificity of an identified test.
Nielsen K. Coeliac disease: alpha-1-antitrypsin contents in jejunal mucosa before and after gluten-free diet. Histopathology. 1984;8(5):759-764. Not sensitivity or specificity of an identified test. [pmid: 6335124].
Nieminen U, Kahri A, Savilahti E, et al. Duodenal disaccharidase activities in the follow-up of villous atrophy in coeliac disease. Scandinavian Journal of Gastroenterology. 2001;36(5):507-510. Not sensitivity or specificity of an identified test. [pmid: 11346204].
Nieto A, Blanco Quiros A, Arranz E, et al. Study of HLA-DQA1 alleles in celiac children. Journal of Investigational Allergology & Clinical Immunology - Official Organ of the International Association of Asthmology (Interasma) and Sociedad Latinoamericana De Alergia E Inmunologia. 1995;5(4):209-215. Unable to extract data. [pmid: 8705011].
Nieuwenhuizen W F, Pieters R H H, Knippels L M J, et al. Is Candida albicans a trigger in the onset of coeliac disease?. Lancet. 2003;361(9375):2152-2154. Not sensitivity or specificity of an identified test. [pmid: 12826451].
Nikkels A F, Arrese Estrada J, Pierard-Franchimont C, et al. CD68 and factor XIIIa expressions in granular-cell tumor of the skin. Dermatology (Basel, Switzerland). 1993;186(2):106-108. Not sensitivity or specificity of an identified test. [pmid: 8094017].
Nilsen E M, Gjertsen H A, Jensen K, et al. Gluten activation of peripheral blood T cells induces a Th0-like cytokine pattern in both coeliac patients and controls. Clinical and Experimental Immunology. 1996;103(2):295-303. Not sensitivity or specificity of an identified test. [pmid: 8565315]. [pmcid: 2200356].
Nilsen E M, Jahnsen F L, Lundin K E, et al. Gluten induces an intestinal cytokine response strongly dominated by interferon gamma in patients with celiac disease. Gastroenterology. 1998;115(3):551-563. Not sensitivity or specificity of an identified test. [pmid: 9721152].
Nilsen E M, Lundin K E, Krajci P, et al. Gluten specific, HLA-DQ restricted T cells from coeliac mucosa produce cytokines with Th1 or Th0 profile dominated by interferon gamma. Gut. 1995;37(6):766-776. Not sensitivity or specificity of an identified test. [pmid: 8537046]. [pmcid: 1382937].
Nilssen D E, Brandtzaeg P, Froland S S, et al. Subclass composition and J-chain expression of the ‘compensatory’ gastrointestinal IgG cell population in selective IgA deficiency. Clinical and Experimental Immunology. 1992;87(2):237-245. Not sensitivity or specificity of an identified test. [pmid: 1735187]. [pmcid: 1554248].
Nishida K, Yamanishi K, Yamada K, et al. Epithelial hyperproliferation and transglutaminase 1 gene expression in Stevens-Johnson syndrome conjunctiva. American Journal of Pathology. 1999;154(2):331-336. Not sensitivity or specificity of an identified test. [pmid: 10027391]. [pmcid: 1850002].
Nishimura T, Horino K, Nishiura H, et al. Apoptotic cells of an epithelial cell line, AsPC-1, release monocyte chemotactic S19 ribosomal protein dimer. Journal of Biochemistry. 2001;129(3):445-454. Not sensitivity or specificity of an identified test. [pmid: 11226885].
Nishiura H, Shibuya Y, Yamamoto T. S19 ribosomal protein cross-linked dimer causes monocyte-predominant infiltration by means of molecular mimicry to complement C5a. Laboratory Investigation 1998;A Journal of Technical Methods and Pathology; 78(12):1615–1623. Not sensitivity or specificity of an identified test
Niveloni S, Dezi R, Pedreira S, et al. Gluten sensitivity in patients with primary biliary cirrhosis. American Journal of Gastroenterology. 1998;93(3):404-408. Not sensitivity or specificity of an identified test. [pmid: 9580141].
Niveloni S, Fiorini A, Dezi R, et al. Usefulness of videoduodenoscopy and vital dye staining as indicators of mucosal atrophy of celiac disease: assessment of interobserver agreement. Gastrointestinal Endoscopy. 1998;47(3):223-229. Not sensitivity or specificity of an identified test. [pmid: 9580349].
Niveloni S, Pedreira S, Sugai E, et al. The natural history of gluten sensitivity: report of two new celiac disease patients resulting from a long-term follow-up of nonatrophic, first-degree relatives. American Journal of Gastroenterology. 2000;95(2):463-468. Not sensitivity or specificity of an identified test. [pmid: 10685751].
Niveloni S, Weksler-Zangen S, Pedreira S, et al. Time course of nitric oxide synthase generation after gluten exposure in the rectal mucosa of gluten-sensitive patients. Scandinavian Journal of Gastroenterology. 2000;35(11):1150-1156. Not sensitivity or specificity of an identified test. [pmid: 11145285].
Niven M J, Caffrey C, Moore R H, et al. T-cell receptor beta-subunit gene polymorphism and autoimmune disease. Hum Immunol. 1990;27(4):360-367. Not sensitivity or specificity of an identified test. [pmid: 1969400].
Noh K W, Poland G A, Murray J A. Hepatitis B Vaccine Nonresponse and Celiac Disease. American Journal of Gastroenterology. 2003;98(10):2289-2292. Not sensitivity or specificity of an identified test. [pmid: 14572581].
Noone C, Menzies I S, Banatvala J E, et al. intestinal permeability and lactose hydrolysis in human rotaviral gastroenteritis assessed simultaneously by non-invasive differential sugar permeation. European Journal of Clinical Investigation. 1986;16(3):217-225. Not sensitivity or specificity of an identified test. [pmid: 3089818].
Norsgaard H, Clark B F, Rattan S I. Distinction between differentiation and senescence and the absence of increased apoptosis in human keratinocytes undergoing cellular aging in vitro. Experimental Gerontology. 1996;31(5):563-570. Not sensitivity or specificity of an identified test. [pmid: 9415111].
Nosari I, Casati A, Mora C, et al. The use of IgA-antiendomysial antibody test for screening coeliac disease in insulin-dependent diabetes mellitus. Diabetes Nutr Metab Clin Exp. 1996;9(5):267-272. Not sensitivity or specificity of an identified test.
Not T, Citta A, Lucchesi A, et al. Anti-endomysium antibody on human umbilical cord vein tissue: an inexpensive and sensitive diagnostic tool for the screening of coeliac disease. European Journal of Pediatrics. 1997;156(8):616-618. Improper control group. [pmid: 9266192].
Not T, Horvath K, Hill I D, et al. Celiac disease risk in the USA: high prevalence of antiendomysium antibodies in healthy blood donors. Scandinavian Journal of Gastroenterology. 1998;33(5):494-498. Not sensitivity or specificity of an identified test. [pmid: 9648988].
Not T, Tommasini A, Tonini G, et al. Undiagnosed coeliac disease and risk of autoimmune disorders in subjects with Type I diabetes mellitus. Diabetologia. 2001;44(2):151-155. Not sensitivity or specificity of an identified test. [pmid: 11270670].
Not T, Ventura A, Peticarari S, et al. A new, rapid, noninvasive screening test for celiac disease. Journal of Pediatrics. 1993;123(3):425-427. Improper control group. [pmid: 8355120].
Not Tarcisio, Faleschini Elena, Tommasini Alberto, et al. Celiac disease in patients with sporadic and inherited cardiomyopathies and in their relatives. European Heart Journal. 2003;24(15):1455-1461. Not sensitivity or specificity of an identified test. [pmid: 12909075].
Nousia-Arvanitakis S, Karagiozoglou-Lamboudes T, Aggouridaki C, et al. Influence of jejunal morphology changes on exocrine pancreatic function in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1999;29(1):81-85. Not sensitivity or specificity of an identified test. [pmid: 10400109].
Novacek G, Miehsler W, Wrba F, et al. Prevalence and clinical importance of hypertransaminasaemia in coeliac disease. European Journal of Gastroenterology & Hepatology. 1999;11(3):283-288. Not sensitivity or specificity of an identified test. [pmid: 10333201].
Novak Petr, Man Petr, Tuckova Ludmila, et al. Monitoring of in vitro deamidation of gliadin peptic fragment by mass spectrometry may reflect one of the molecular mechanisms taking place in celiac disease development. Journal of Mass Spectrometry - Jms. 2002;37(5):507-511. Not sensitivity or specificity of an identified test. [pmid: 12112756].
Nowak T V, Ghishan F K, Schulze-Delrieu K. Celiac sprue in Down Syndrome: considerations on a pathogenetic link. American Journal of Gastroenterology. 1983;78(5):280-283. Not sensitivity or specificity of an identified test. [pmid: 6221657].
Nunes I, Gleizes P E, Metz C N, et al. Latent transforming growth factor-beta binding protein domains involved in activation and transglutaminase-dependent cross-linking of latent transforming growth factor-beta. Journal of Cell Biology. 1997;136(5):1151-1163. Not sensitivity or specificity of an identified test. [pmid: 9060478].
Nurminskaya M V, Linsenmayer T F. Immunohistological analysis of transglutaminase factor XIIIA expression in mouse embryonic growth plate. J Orthop Res. 2002;20(3):575-578. Not sensitivity or specificity of an identified test. [pmid: 12038633].
Nuti R, Martini G, Valenti R, et al. Prevalence of undiagnosed coeliac syndrome in osteoporotic women. Journal of Internal Medicine. 2001;250(4):361-366. Not sensitivity or specificity of an identified test. [pmid: 11576323].
Nyren O, Adami H-O, Gustavsson S. The ‘epigastric distress syndrome’. A possible disease entity identified by history and endoscopy in patients with nonulcer dyspepsia. Journal of Clinical Gastroenterology. 1987;9(3):303-309. Not sensitivity or specificity of an identified test. [pmid: 3655274].
O'Brien M, Colwell R. Modified taurocholate-tellurite-gelatin agar for improved differentiation of Vibrio species. Journal of Clinical Microbiology. 1985;22(6):1011-1013. Not sensitivity or specificity of an identified test. [pmid: 3934207]. [pmcid: 271868].
O'Brien R M, Thomas W R, Nicholson I, et al. An immunogenetic analysis of the T-cell recognition of the major house dust mite allergen Der p 2: Identification of high- and low-responder HLA-DQ alleles and localization of T-cell epitopes. Immunology. 1995;86(2):176-182. Not sensitivity or specificity of an identified test. [pmid: 7490115]. [pmcid: 1383992].
O'Donnell B F, O'Neill C M, Francis D M, et al. Human leucocyte antigen class II associations in chronic idiopathic urticaria. Br J Dermatol. 1999;140(5):853-858. Not sensitivity or specificity of an identified test. [pmid: 10354022].
O'Driscoll B R, Stevens F M, O'Gorman T A, et al. HLA type of patients with coeliac disease and malignancy in the west of Ireland. Gut. 1982;23(8):662-665. Not sensitivity or specificity of an identified test. [pmid: 7095561]. [pmcid: 1419133].
O'Farrelly C. Is villous atrophy always and only the result of gluten sensitive disease of the intestine?. European Journal of Gastroenterology & Hepatology. 2000;12(6):605-608. Not sensitivity or specificity of an identified test. [pmid: 10912475].
O'Farrelly C, Feighery C, O'Briain D S, et al. Humoral response to wheat protein in patients with coeliac disease and enteropathy associated T cell lymphoma. British Medical Journal (Clinical Research Ed.). 1986;293(6552):908-910. Not sensitivity or specificity of an identified test. [pmid: 3094712]. [pmcid: 1341707].
O'Farrelly C, Graeme-Cook F, Hourihane D O, et al. Histological changes associated with wheat protein antibodies in the absence of villous atrophy. Journal of Clinical Pathology. 1987;40(10):1228-1230. Unable to extract data. [pmid: 3680547]. [pmcid: 1141200].
O'Farrelly C, Kelly J, Hekkens W, et al. Alpha gliadin antibody levels: a serological test for coeliac disease. British Medical Journal (Clinical Research Ed.). 1983;286(6383):2007-2010. Serology <1990. [pmid: 6409205]. [pmcid: 1548488].
O'Farrelly C, O'Mahony C, Graeme-Cook F, et al. Gliadin antibodies identify gluten-sensitive oral ulceration in the absence of villous atrophy. Journal of Oral Pathology & Medicine - Official Publication of the International Association of Oral Pathologists and the American Academy of Oral Pathology. 1991;20(10):476-478. Not sensitivity or specificity of an identified test. [pmid: 1753350].
O'Grady J G, Stevens F M, McCarthy C F. Celiac disease: does hyposplenism predispose to the development of malignant disease?. American Journal of Gastroenterology. 1985;80(1):27-29. Not sensitivity or specificity of an identified test. [pmid: 3966450].
O'Grady J G, Stevens F M, McCarthy C F. Genetic influences on splenic function in coeliac disease. Gut. 1985;26(10):1004-1007. Not sensitivity or specificity of an identified test. [pmid: 3876972]. [pmcid: 1432950].
O'Grady J G, Stevens F M, Harding B, et al. Effect of splenectomy and the functional hyposplenism of coeliac disease on auto-antibody formation. Irish Journal of Medical Science. 1984;153(10):351-354. Not sensitivity or specificity of an identified test. [pmid: 6334666].
O'Grady J G, Stevens F M, Harding B, et al. Hyposplenism and gluten-sensitive enteropathy. Natural history, incidence, and relationship to diet and small bowel morphology. Gastroenterology. 1984;87(6):1326-1331. Not sensitivity or specificity of an identified test. [pmid: 6489698].
O'Grady J G, Stevens F M, Keane R, et al. Intestinal lactase, sucrase, and alkaline phosphatase in 373 patients with coeliac disease. Journal of Clinical Pathology. 1984;37(3):298-301. Not sensitivity or specificity of an identified test. [pmid: 6421895]. [pmcid: 498703].
O'Halloran E T, Read M, Morrissey-Walsh E M. Coeliac disease in children: Problems in diagnosis and management. Ir Med J. 1985;78(7):188-191. Not sensitivity or specificity of an identified test. [pmid: 4030295].
O'Halloran E T, Read M, Barry R G, et al. The management of coeliac disease. Irish Medical Journal. 1998;91(6):199-202. Not sensitivity or specificity of an identified test. [pmid: 10069127].
O'Keefe S J. Nutrition and gastrointestinal disease. Scandinavian Journal of Gastroenterology. Supplement 1996;22052–59. Not sensitivity or specificity of an identified test
O'Keeffe J, Lynch S, Whelan A, et al. Flow cytometric measurement of intracellular migration inhibition factor and tumour necrosis factor alpha in the mucosa of patients with coeliac disease. Clinical and Experimental Immunology. 2001;125(3):376-382. Not sensitivity or specificity of an identified test. [pmid: 11531944]. [pmcid: 1906145].
O'Keeffe J, Mills K, Jackson J, et al. T cell proliferation, MHC class II restriction and cytokine products of gliadin-stimulated peripheral blood mononuclear cells (PBMC). Clinical and Experimental Immunology. 1999;117(2):269-276. Not sensitivity or specificity of an identified test. [pmid: 10444257]. [pmcid: 1905335].
O'Laughlin J C, Di Giovanni A M. Psoriatic enteropathy: Report of case and review of literature. J Am Osteopath Assoc. 1979;79(2):107-112. Not sensitivity or specificity of an identified test. [pmid: 489440].
O'Leary C, Walsh C H, Wieneke P, et al. Coeliac disease and autoimmune Addison's disease: a clinical pitfall. Qjm - Monthly Journal of the Association of Physicians. 2002;95(2):79-82. Not sensitivity or specificity of an identified test. [pmid: 11861954].
O'Mahony S, Arranz E, Barton J R, et al. Dissociation between systemic and mucosal humoral immune responses in coeliac disease. Gut. 1991;32(1):29-35. Not sensitivity or specificity of an identified test. [pmid: 1991635]. [pmcid: 1379209].
O'Mahony S, Barton J R, Crichton S, et al. Appraisal of gut lavage in the study of intestinal humoral immunity. Gut. 1990;31(12):1341-1344. Not sensitivity or specificity of an identified test. [pmid: 2265775]. [pmcid: 1378753].
O'Mahony S, Vestey J P, Ferguson A. Similarities in intestinal humoral immunity in dermatitis herpetiformis without enteropathy and in coeliac disease. Lancet. 1990;335(8704):1487-1490. Not sensitivity or specificity of an identified test. [pmid: 1972433].
Oberhuber G. Histopathology of celiac disease. Biomedicine & Pharmacotherapy = Biomedecine & Pharmacotherapie. 2000;54(7):368-372. Review article.
Oberhuber G, Granditsch G, Vogelsang H. The histopathology of coeliac disease: time for a standardized report scheme for pathologists. European Journal of Gastroenterology & Hepatology. 1999;11(10):1185-1194. Not sensitivity or specificity of an identified test. [pmid: 10524652].
Oberhuber G, Schwarzenhofer M, Vogelsang H. In vitro model of the pathogenesis of celiac disease. Digestive Diseases (Basel, Switzerland). 1998;16(6):341-344. Not sensitivity or specificity of an identified test. [pmid: 10207219].
Oderda G, Forni M, Morra I, et al. Endoscopic and histologic findings in the upper gastrointestinal tract of children with coeliac disease. Journal of Pediatric Gastroenterology and Nutrition. 1993;16(2):172-177. Not sensitivity or specificity of an identified test. [pmid: 8450385].
Ofosu M H, Dunston G, Henry L, et al. HLA-DQ3 is associated with Graves' disease in African-Americans. Immunological Investigations. 1996;25(12):103-110. Not sensitivity or specificity of an identified test. [pmid: 8675226].
Ogawa H, Goldsmith L A. Human epidermal transglutaminase II. Immunologic properties. Journal of Investigative Dermatology. 1977;68(1):32-35. Not sensitivity or specificity of an identified test. [pmid: 12234].
Oh J H, MacLean L D. Diseases associated with specific HL-A antigens. Canadian Medical Association Journal. 1975;112(11):1315-1318. Not sensitivity or specificity of an identified test. [pmid: 1092451]. [pmcid: 1956123].
Ohashi H, Itoh Y, Birckbichler P J, et al. Purification and characterization of rat brain transglutaminase. Journal of Biochemistry. 1995;118(6):1271-1278. Not sensitivity or specificity of an identified test. [pmid: 8720146].
Oiso M, Nishi T, Ishikawa T, et al. Differential binding of peptides substituted at putative C-terminal anchor residues to HLA-DQ8 and DQ9 differing only at betasup 5sup 7. Hum Immunol. 1997;52(1):47-53. Not sensitivity or specificity of an identified test. [pmid: 9021409].
Okamoto M, Yamamoto T, Matsubara S, et al. Factor XIII-dependent generation of 5th complement component(C5)-derived monocyte chemotactic factor coinciding with plasma clotting. Biochimica Et Biophysica Acta. 1992;1138(1):53-61. Not sensitivity or specificity of an identified test. [pmid: 1346574].
Oktedalen O, Skar V, Dahl E. Changes in small intestinal structure and function in HIV-infected patients with chronic diarrhoea. Scandinavian Journal of Infectious Diseases. 1998;30(5):459-463. Not sensitivity or specificity of an identified test. [pmid: 10066044].
Okuno M, Kojima S, Moriwaki H. Chemoprevention of hepatocellular carcinoma: concept, progress and perspectives. Journal of Gastroenterology and Hepatology. 2001;16(12):1329-1335. Not sensitivity or specificity of an identified test. [pmid: 11851828].
Okuno M, Sano T, Matsushima-Nishiwaki R, et al. Apoptosis induction by acyclic retinoid: a molecular basis of ‘clonal deletion’ therapy for hepatocellular carcinoma. Japanese Journal of Clinical Oncology. 2001;31(8):359-362. Not sensitivity or specificity of an identified test. [pmid: 11574627].
Olaussen R W, Johansen F E, Lundin K E A, et al. Interferon-gamma-secreting T cells localize to the epithelium in coeliac disease. Scand J Immunol. 2002;56(6):652-664. Not sensitivity or specificity of an identified test. [pmid: 12472679].
Olds G, McLoughlin R, O'Morian C, et al. Celiac disease for the endoscopist. Gastrointest Endosc. 2002;56(3):407-415. Not sensitivity or specificity of an identified test. [pmid: 12196781].
Olerup O, Olsson R, Hultcrantz R, et al. HLA-DR and HLA-DQ are not markers for rapid disease progression in primary sclerosing cholangitis. Gastroenterology. 1995;108(3):870-878. Not sensitivity or specificity of an identified test. [pmid: 7875491].
Oliva A, Armas H, Farina J B. HPLC determination of polyethylene glycol 400 in urine: Oligomeric profile in healthy and celiac disease subjects. Clinical Chemistry. 1994;40(8):1571-1574. Not sensitivity or specificity of an identified test. [pmid: 8044999].
Oliver R T D. Histocompatibility antigens and human disease. Br J Hosp Med. 1977;18(5):449-459. Not sensitivity or specificity of an identified test. [pmid: 413599].
Oliverio S, Amendola A, Di Sano F, et al. Tissue transglutaminase-dependent posttranslational modification of the retinoblastoma gene product in promonocytic cells undergoing apoptosis. Mol Cell Biol. 1997;17(10):6040-6048. Not sensitivity or specificity of an identified test. [pmid: 9315663]. [pmcid: 232453].
Oliverio S, Amendola A, Rodolfo C, et al. Inhibition of “tissue” transglutaminase increases cell survival by preventing apoptosis. Journal of Biological Chemistry. 1999;274(48):34123-34128. Not sensitivity or specificity of an identified test. [pmid: 10567382].
Olives PrJ. Coeliac disease and gluten intolerance: New data for a new method of treatment. Rev Med Liban. 2000;12(3):127-128. Not sensitivity or specificity of an identified test.
Olorundare O E, Peyruchaud O, Albrecht R M, et al. Assembly of a fibronectin matrix by adherent platelets stimulated by lysophosphatidic acid and other agonists. Blood. 2001;98(1):117-124. Not sensitivity or specificity of an identified test. [pmid: 11418470].
Olsen W A. A pathophysiologic approach to diagnosis of malabsorption. American Journal of Medicine. 1979;67(6):1007-1013. Not sensitivity or specificity of an identified test. [pmid: 42313].
Olsen W A. A practical approach to diagnosis of disorders of intestinal absorption. New England Journal of Medicine. 1971;285(24):1358-1361. Not sensitivity or specificity of an identified test. [pmid: 4941276].
Olson D J, Fujimura M, Swanson P, et al. Immunohistochemical features of Paget's disease of the vulva with and without adenocarcinoma. Int J Gynecol Pathol. 1991;10(3):285-295. Not sensitivity or specificity of an identified test. [pmid: 1655667].
Olsson R, Kagevi I, Rydberg L. On the concurrence of primary biliary cirrhosis and intestinal villous atrophy. Scandinavian Journal of Gastroenterology. 1982;17(5):625-628. Not sensitivity or specificity of an identified test. [pmid: 6983714].
Orgad S, Avigad S, Jonas A, et al. Immunogenetics of childhood celiac disease: the association with HDA DR3 and DR7 in unrelated patients with multiply affected families. Israel Journal of Medical Sciences. 1981;17(11):1041-1044. Not sensitivity or specificity of an identified test. [pmid: 6797985].
Orru S, Caputo I, D'Amato A, et al. Proteomics identification of acyl-acceptor and acyl-donor substrates for transglutaminase in a human intestinal epithelial cell line. Implications for celiac disease. J Biol Chem. 2003;278(34):31766-31773. Not sensitivity or specificity of an identified test. [pmid: 12799366].
Osa A, Almenar L, Palencia M, et al. Antigens of the major histocompatibility system in ischemic heart disease and idiopathic dilated cardiomyopathy. Clin Cardiol. 1999;22(4):292-296. Not sensitivity or specificity of an identified test. [pmid: 10198739].
Osman A A, Gunnel T, Dietl A, et al. B cell epitopes of gliadin. Clinical and Experimental Immunology. 2000;121(2):248-254. Not sensitivity or specificity of an identified test. [pmid: 10931138]. [pmcid: 1905697].
Osman A A, Richter T, Stern M et al. The IgA subclass distributions of endomysium and gliadin antibodies in human sera are different. Clinica Chimica Acta 1996;International Journal of Clinical Chemistry; 255(2):145–152. Not sensitivity or specificity of an identified test
Osman A A, Uhlig H, Thamm B, et al. Use of the phage display technique for detection of epitopes recognized by polyclonal rabbit gliadin antibodies. Febs Letters. 1998;433(12):103-107. Not sensitivity or specificity of an identified test. [pmid: 9738942].
Osman Awad A, Richter Thomas, Stern Martin, et al. Production of recombinant human tissue transglutaminase using the baculovirus expression system, and its application for serological diagnosis of coeliac disease. European Journal of Gastroenterology & Hepatology. 2002;14(11):1217-1223. test-specific exclusion. [pmid: 12439116].
Otley C, Hall R P. Dermatitis herpetiformis. Dermatol Clin. 1990;8(4):759-769. Not sensitivity or specificity of an identified test. [pmid: 2249367].
Otley C C, Hall R P. The pathogenesis of dermatitis herpetiformis. Clinics in Dermatology. 1991;9(3):313-323. Not sensitivity or specificity of an identified test. [pmid: 1806218].
Otley C C, Wenstrup R J, Hall R P. DNA sequence analysis and restriction fragment length polymorphism (RFLP) typing of the HLA-DQw2 alleles associated with dermatitis herpetiformis. Journal of Investigative Dermatology. 1991;97(2):318-322. Not sensitivity or specificity of an identified test. [pmid: 1677025].
Ots M, Uibo O, Metskula K, et al. IgA-antigliadin antibodies in patients with IgA nephropathy: the secondary phenomenon?. American Journal of Nephrology. 1999;19(4):453-458. Not sensitivity or specificity of an identified test. [pmid: 10460933].
Ott D J. Celiac disease: biopsy or enteroclysis better for evaluating response to a gluten-free diet?. American Journal of Gastroenterology. 1997;92(4):715-716. Not sensitivity or specificity of an identified test. [pmid: 9128339].
Ottaway C A. Activated T cells and genetic restriction in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1994;19(2):250-251. Not sensitivity or specificity of an identified test. [pmid: 7815251].
Otto H F, Bettmann I, Weltzien v J, et al. Primary intestinal lymphomas. Virchows Arch Abt A Pathol Anat. 1981;391(1):9-31. Not sensitivity or specificity of an identified test.
Owens D W, Brunton V G, Parkinson E K, et al. E-cadherin at the cell periphery is a determinant of keratinocyte differentiation in vitro. Biochemical and Biophysical Research Communications. 2000;269(2):369-376. Not sensitivity or specificity of an identified test. [pmid: 10708559].
Oxentenko A S, Murray J A. Celiac disease and dermatitis herpetiformis: The spectrum of gluten-sensitive enteropathy. International Journal of Dermatology. 2003;42(8):585-587. Not sensitivity or specificity of an identified test. [pmid: 12890099].
Oxentenko Amy S, Grisolano Scott W, Murray Joseph A, et al. The insensitivity of endoscopic markers in celiac disease. American Journal of Gastroenterology. 2002;97(4):933-938. Not sensitivity or specificity of an identified test. [pmid: 12003429].
Ozgenc F, Aksu G, Aydogdu S, et al. Association between anti-endomysial antibody and total intestinal villous atrophy in children with coeliac disease. Journal of Postgraduate Medicine. 2003;49(1):21-24. Improper control group. [pmid: 12865566].
Ozkan T, Ozeke T, Meral A. Gliadin-specific IgA antibodies in breast milk. Journal of International Medical Research. 2000;28(5):234-240. Not sensitivity or specificity of an identified test. [pmid: 11092234].
Ozkara C, Altintas A, Yilmaz E, et al. An association between mesial temporal lobe epilepsy with hippocampal sclerosis and human leukocyte antigens. Epilepsia. 2002;43(3):236-239. Not sensitivity or specificity of an identified test. [pmid: 11906507].
Pacheco L S, Sotto M N. Factor XIIIa+ dermal dendrocytest in erythema elevatum diutinum and ordinary cutaneous leukocytoclastic vasculitis lesions. Journal of Cutaneous Pathology. 2000;27(3):136-140. Not sensitivity or specificity of an identified test. [pmid: 10728816].
Packer S M, Charlton V, Keeling J W, et al. Gluten challenge in treated coeliac disease. Archives of Disease in Childhood. 1978;53(6):449-455. Not sensitivity or specificity of an identified test. [pmid: 686770].
Packer S, Rowlatt R J, Harries J T. Proceedings: Reappraisal of a past diagnosis of “coeliac disease”. Archives of Disease in Childhood. 1974;49(10):819. Not sensitivity or specificity of an identified test. [pmid: 4429369].
Paddenberg R, Flocke K, Elsasser H P, et al. Phenotypical changes of a human pancreatic adenocarcinoma cell line after selection on laminin-1/nidogen (LM/Ng) substratum. European Journal of Cell Biology. 1998;76(4):251-264. Not sensitivity or specificity of an identified test. [pmid: 9765055].
Padmanabhan Vijayalakshmi, Callas Peter W, Li Shuan C, et al. Histopathological features of the terminal ileum in lymphocytic and collagenous colitis: a study of 32 cases and review of literature. Modern Pathology - an Official Journal of the United Statest and Canadian Academy of Pathology, Inc. 2003;16(2):115-119. Not sensitivity or specificity of an identified test.
Padykula H A, Strauss E W, Ladman A J et al. A morphologic and histochemical analysis of the human jejunal epithelium in nontropical sprue. Gastroenterology 1968;54(4):SupplUnable to extract data
Paerregaard A, Vilien M, Krasilnikoff P A, et al. Supposed coeliac disease during childhood and its presentation 14–38 years later. Scandinavian Journal of Gastroenterology. 1988;23(1):65-70. Not sensitivity or specificity of an identified test. [pmid: 3344399].
Page S R, Lloyd C A, Hill P G, et al. The prevalence of coeliac disease in adult diabetes mellitus. Qjm - Monthly Journal of the Association of Physicians. 1994;87(10):631-637. Not sensitivity or specificity of an identified test. [pmid: 7987659].
Paimela L, Kurki P, Leirisalo-Repo M, et al. Gliadin immune reactivity in patients with rheumatoid arthritis. Clinical and Experimental Rheumatology. 1995;13(5):603-607. Not sensitivity or specificity of an identified test. [pmid: 8575138].
Palavecino E A, Mota A H, Awad J, et al. HLA and celiac disease in Argentina: involvement of the DQ subregion. Disease Markers. 1990;8(1):5-10. Improper control group. [pmid: 2311351].
Pallet V, Azais-Braesco V, Enderlin V, et al. Aging decreases retinoic acid and triiodothyronine nuclear expression in rat liver: Exogenous retinol and retinoic acid differentially modulate this decreased expression. Mech Ageing Dev. 1998;99(2):123-136. Not sensitivity or specificity of an identified test.
Palosuo K, Alenius H, Varjonen E, et al. Rye gamma-70 and gamma-35 secalins and barley gamma-3 hordein cross-react with omega-5 gliadin, a major allergen in wheat-dependent, exercise-induced anaphylaxis. Clinical and Experimental Allergy - Journal of the British Society for Allergy and Clinical Immunology. 2001;31(3):466-473. Not sensitivity or specificity of an identified test. [pmid: 11260160].
Palosuo Kati, Varjonen Elina, Nurkkala Jenni, et al. Transglutaminase-mediated cross-linking of a peptic fraction of omega-5 gliadin enhances IgE reactivity in wheat-dependent, exercise-induced anaphylaxis. Journal of Allergy and Clinical Immunology. 2003;111(6):1386-1392. Not sensitivity or specificity of an identified test. [pmid: 12789243].
Pani M A, Van Autreve J, Van der. Non-transmitted maternal HLA DQ2 or DQ8 alleles and risk of Type I diabetes in offspring: the importance of foetal or post partum exposure to diabetogenic molecules. Diabetologia. 2002;45(9):1340-1343. Not sensitivity or specificity of an identified test. [pmid: 12242468].
Pani Michael A, Seidl Christian, Bieda Katrin, et al. Preliminary evidence that an endogenous retroviral long-terminal repeat (LTR13) at the HLA-DQB1 gene locus confers susceptibility to Addison's disease. Clinical Endocrinology. 2002;56(6):773-777. Not sensitivity or specificity of an identified test. [pmid: 12072047].
Pani Michael A, Wood Jeffrey P, Bieda Katrin, et al. The variable endogenous retroviral insertion in the human complement C4 gene: a transmission study in type I diabetes mellitus. Human Immunology. 2002;63(6):481-484. Not sensitivity or specificity of an identified test. [pmid: 12039523].
Papadatou B, Crino A, Giannotti A, et al. Antiendomysial and antigliadin antibodies in patients with Down syndrome. Dev Brain Dysfunct. 1996;9(23):129-132. Not sensitivity or specificity of an identified test.
Papadopoulos A J, Schwartz R A, Krysicka Janniger C. Alopecia areata: Emerging concepts. Acta Dermatovenerol Alp Panonica Adriat. 2000;9(3):83-90. Not sensitivity or specificity of an identified test.
Papadopoulos G K, Wijmenga C, Koning F. Interplay between genetics and the environment in the development of celiac disease: perspectives for a healthy life. Journal of Clinical Investigation. 2001;108(9):1261-1266. Not sensitivity or specificity of an identified test. [pmid: 11696566]. [pmcid: 209453].
Papadopoulos K I, Sjoberg K, Lindgren S, et al. Evidence of gastrointestinal immune reactivity in patients with sarcoidosis. Journal of Internal Medicine. 1999;245(5):525-531. Not sensitivity or specificity of an identified test. [pmid: 10363754].
Papouchado B G, Chapoval S P, Marietta E V, et al. Cockroach allergen-induced eosinophilic airway inflammation in HLA-DQ/human CD4SUP+ transgenic mice. J Immunol. 2001;167(8):4627-4634. Not sensitivity or specificity of an identified test. [pmid: 11591792].
Paranos S, Nikolic G. Lack of cross-reactivity between casein and gliadin in sera from coeliac disease patients. International Archives of Allergy and Immunology. 1998;117(2):152-154. Not sensitivity or specificity of an identified test. [pmid: 9784660].
Pardi D S, Ramnath V R, Loftus E V, et al. Lymphocytic colitis: Clinical features, treatment, and outcomes. American Journal of Gastroenterology. 2002;97(11):2829-2833. Not sensitivity or specificity of an identified test. [pmid: 12425555].
Parent D, Bernard B A, Desbas C, et al. Spreading of psoriatic plaques: alteration of epidermal differentiation precedes capillary leakiness and anomalies in vascular morphology. Journal of Investigative Dermatology. 1990;95(3):333-340. Not sensitivity or specificity of an identified test. [pmid: 2384691].
Parham D M, Coghill G, Robertson A J. Critical evaluation of monoclonal antibody staining in breast carcinoma. Journal of Clinical Pathology. 1989;42(8):810-813. Not sensitivity or specificity of an identified test. [pmid: 2475527]. [pmcid: 1142056].
Park M H, Hwang Y-S, Park K S, et al. HLA haplotypes in Koreans based on 107 families. Tissue Antigens. 1998;51(4 I):347-355. Not sensitivity or specificity of an identified test. [pmid: 9583806].
Park Y-S, Sanjeevi C B, Robles D, et al. Additional association of intra-MHC genes, MICA and D6S273, with Addison's disease. Tissue Antigens. 2002;60(2):155-163. Not sensitivity or specificity of an identified test. [pmid: 12392510].
Parke A L. Gastrointestinal disorders and rheumatic diseases. Curr Opin Rheumatol. 1993;5(1):79-84. Not sensitivity or specificity of an identified test. [pmid: 8435293].
Parkkonen P, Hyoty H, Ilonen J, et al. Antibody reactivity to an Epstein-Barr virus BERF4-encoded epitope occurring also in Asp-57 region of HLA-DQ8 beta chain. Clinical and Experimental Immunology. 1994;95(2):287-293. Not sensitivity or specificity of an identified test. [pmid: 7508347]. [pmcid: 1534924].
Parmentier L, Blanchet-Bardon C, Nguyen S, et al. Autosomal recessive lamellar ichthyosis: identification of a new mutation in transglutaminase 1 and evidence for genetic heterogeneity. Human Molecular Genetics. 1995;4(8):1391-1395. Not sensitivity or specificity of an identified test. [pmid: 7581379].
Parnell N, Ciclitira P J. Celiac disease. Curr Opin Gastroenterol. 1999;15(2):120-124. Not sensitivity or specificity of an identified test. [pmid: 17023931].
Parnell N D, Ciclitira P J. Review article: coeliac disease and its management. Alimentary Pharmacology & Therapeutics. 1999;13(1):1-13. Not sensitivity or specificity of an identified test. [pmid: 10383530].
Parrot Isabelle, Huang Philip C, Khosla Chaitan. Circular dichroism and nuclear magnetic resonance spectroscopic analysis of immunogenic gluten peptides and their analogs. Journal of Biological Chemistry. 2002;277(47):45572-45578. Not sensitivity or specificity of an identified test. [pmid: 12324465].
Parsons K T, Kwok W W, Gaur L K, et al. Increased frequency of HLA class II alleles DRB1*0301 and DQB1*0201 in Lambert-Eaton myasthenic syndrome without associated cancer. Hum Immunol. 2000;61(8):828-833. Not sensitivity or specificity of an identified test. [pmid: 10980394].
Partanen J. The HLA-DRB4 gene does not explain genetic susceptibility in HLA-DQ2-negative celiac disease. Immunogenetics. 2000;51(3):249-250. Not sensitivity or specificity of an identified test. [pmid: 10752637].
Partanen J, Milner C, Campbell R D, et al. HLA-linked heat-shock protein 70 (HSP70-2) gene polymorphism and celiac disease. Tissue Antigens. 1993;41(1):15-19. Not sensitivity or specificity of an identified test. [pmid: 8096093].
Parveen S, Morshed S A, Arima K, et al. Antibodies to Ro/La, Cenp-B, and snRNPs antigens in autoimmune hepatitis of North America versus Asia: Patterns of immunofluorescence, ELISA reactivities, and HLA association. Digestive Diseases and Sciences. 1998;43(6):1322-1331. Not sensitivity or specificity of an identified test. [pmid: 9635626].
Pasquali D, Rossi V, Prezioso D, et al. Changes in tissue transglutaminase activity and expression during retinoic acid-induced growth arrest and apoptosis in primary cultures of human epithelial prostate cells. Journal of Clinical Endocrinology and Metabolism. 1999;84(4):1463-1469. Not sensitivity or specificity of an identified test. [pmid: 10199796].
Passarge E, Valentine-Thon E. Everything the pediatrician ever wanted to know about HLA but was afraid to ask. European Journal of Pediatrics. 1980;133(2):93-100. Not sensitivity or specificity of an identified test. [pmid: 6988220].
Pasternack A, Collin P, Mustonen J, et al. Glomerular IgA deposits in patients with celiac disease. Clinical Nephrology. 1990;34(2):56-60. Not sensitivity or specificity of an identified test. [pmid: 2225554].
Pastore R A. Celiac disease: Endoscopic observations. American Journal of Gastroenterology. 1974;61(6):478-480. Not sensitivity or specificity of an identified test. [pmid: 4835422].
Patel R S, Johlin F C, Murray J A. Celiac disease and recurrent pancreatitis. Gastrointestinal Endoscopy. 1999;50(6):823-827. Not sensitivity or specificity of an identified test. [pmid: 10570344].
Paterson C R, Burns J. Coeliac disease presenting with vitamin D deficiency in the elderly. Eur J Intern Med. 1991;2(2):73-76. Not sensitivity or specificity of an identified test.
Patey N, Scoazec J Y, Cuenod-Jabri B, et al. Distribution of cell adhesion molecules in infants with intestinal epithelial dysplasia (tufting enteropathy). Gastroenterology. 1997;113(3):833-843. Not sensitivity or specificity of an identified test. [pmid: 9287975].
Patey-Mariaud de, Serre Cellier C, Jabri B, et al. Distinction between coeliac disease and refractory sprue: a simple immunohistochemical method. Histopathology. 2000;37(1):70-77. Not sensitivity or specificity of an identified test. [pmid: 10931221].
Patinen P, Bjorksten F, Malmstrom M, et al. Salivary and serum IgA antigliadin antibodies in dermatitis herpetiformis. European Journal of Oral Sciences. 1995;103(5):280-284. Not sensitivity or specificity of an identified test. [pmid: 8521118].
Patinen P, Savilahti E, Hietanen J, et al. Intraepithelial lymphocytest bearing the gamma/delta receptor in the oral and jejunal mucosa in patients with dermatitis herpetiformis. European Journal of Oral Sciences. 1997;105(2):130-135. Not sensitivity or specificity of an identified test. [pmid: 9151065].
Patney N L, Srivastava V K, Wahal p k, et al. A study of fat malabsorption and jejunal muscosal biopsy in diabetic neuropathy: a preliminary report. Journal of the Association of Physicians of India. 1973;21(9):777-785. Not sensitivity or specificity of an identified test. [pmid: 4794854].
Patterson R N, Johnston S D. Iron deficiency anaemia: Are the British Society of Gastroenterology guidelines being adhered to?. Postgrad Med J. 2003;79(930):226-228. Not sensitivity or specificity of an identified test. [pmid: 12743344].
Paulley J W. Determinants of adult celiac disease. New England Journal of Medicine. 1971;284(15):916. Not sensitivity or specificity of an identified test. [pmid: 5549837].
Paulsen G, Lundin K E, Gjertsen H A, et al. HLA-DQ2-restricted T-cell recognition of gluten-derived peptides in celiac disease. Influence of amino acid substitutions in the membrane distal domain of DQ beta 1*0201. Human Immunology. 1995;42(2):145-153. Not sensitivity or specificity of an identified test. [pmid: 7744618].
Pavone L, Fiumara A, Bottaro G, et al. Autism and celiac disease: failure to validate the hypothesis that a link might exist. Biological Psychiatry. 1997;42(1):72-75. Not sensitivity or specificity of an identified test. [pmid: 9193744].
Pearce Allum B, Sinclair David, Duncan Hamish D, et al. Use of the anti-endomysial antibody test to diagnose coeliac disease in clinical practice. Clinical Laboratory. 2002;48(56):319-325. Improper control group. [pmid: 12071583].
Peces R, De la, Torre M, et al. Prospective analysis of the factors influencing the antibody response to hepatitis B vaccine in hemodialysis patients. Am J Kidney Dis. 1997;29(2):239-245. Not sensitivity or specificity of an identified test. [pmid: 9016896].
Pecsi G. Genetic associations and immunopathogenesis of coeliac disease. Acta Physiologica Hungarica. 2000;87(4):339-353. Not sensitivity or specificity of an identified test. [pmid: 11732888].
Pehamberger H, Gschnait F, Menzel J, et al. Failure to detect gliadin or gliadin binding sitest in the skin of patients with dermatitis herpetiformis: immunofluorescence, organ culture and autoradiographic studies. Journal of Investigative Dermatology. 1979;73(2):174-175. Not sensitivity or specificity of an identified test. [pmid: 379243].
Pelkonen P, Savilahti E, Makela A L. Persistent and transient IgA deficiency in juvenile rheumatoid arthritis. Scand J Rheumatol. 1983;12(3):273-279. Not sensitivity or specificity of an identified test. [pmid: 6623018].
Pellecchia M T, Ambrosio G, Salvatore E, et al. Possible gluten sensitivity in multiple system atrophy. Neurology. 2002;59(7):1114-1115. Not sensitivity or specificity of an identified test. [pmid: 12370481].
Pellecchia M T, Scala R, Filla A, et al. Idiopathic cerebellar ataxia associated with celiac disease: lack of distinctive neurological features. Journal of Neurology, Neurosurgery, and Psychiatry. 1999;66(1):32-35. Not sensitivity or specificity of an identified test. [pmid: 9886447].
Pellegrini G, Scotta M S, Soardo S, et al. Elevated IgA anti-gliadin antibodies in juvenile chronic arthritis. Clinical and Experimental Rheumatology. 1991;9(6):653-656. Not sensitivity or specificity of an identified test. [pmid: 1764847].
Pena A S, Mearin M L. Aetiopathogenesis of coeliac disease. Acta Gastroenterol Belg. 1986;49(4):428-434. Not sensitivity or specificity of an identified test. [pmid: 3107303].
Pena A S, Wijmenga C. Genetic factors underlying gluten-sensitive enteropathy. Current Allergy and Asthma Reports. 2001;1(6):526-533. Not sensitivity or specificity of an identified test. [pmid: 11892082].
Pena A S, Garrote J A, Crusius J B. Advances in the immunogenetics of coeliac disease. Clues for understanding the pathogenesis and disease heterogeneity. Scandinavian Journal of Gastroenterology.Supplement 1998;22556–58. Not sensitivity or specificity of an identified test
Pena A S, Mann D L, Hague N E, et al. Genetic basis of gluten-sentitive enteropathy. Gastroenterology. 1978;75(2):230-235. Not sensitivity or specificity of an identified test. [pmid: 307512].
Pena A S, Mearin M L, Biemond I. Genetics and heterogeneity in coeliac disease. Acta Gastro-Enterologica Belgica. 1984;47(2):134-135. Not sensitivity or specificity of an identified test. [pmid: 6485714].
Pena A S, Truelove S C, Whitehead R. Disaccharidase activity and jejunal morphology in coeliac disease. Quarterly Journal of Medicine. 1972;41(164):457-476. Unable to extract data. [pmid: 4636546].
Pena A S, Van Nieuwkoop J, Schuit H R E. Transient paraproteinaemia in a patient with coeliac disease. Gut. 1976;17(9):735-739. Not sensitivity or specificity of an identified test. [pmid: 976814]. [pmcid: 1411281].
Pena-Penabad C, de Unamuno P, Garcia Silva J, et al. Altered expression of immunoreactive involucrin in lamellar ichthyosis. European Journal of Dermatology - Ejd. 1999;9(3):197-201. Not sensitivity or specificity of an identified test. [pmid: 10210784].
Penedo-Pita M, Peteiro-Cartelle J. Increased serum levels of interleukin-2 and soluble interleukin-2 receptor in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1991;12(1):56-60. Not sensitivity or specificity of an identified test. [pmid: 2061780].
Penfornis A, Tuomilehto-Wolf E, Faustman D L, et al. Analysis of TAP2 polymorphisms in finnish individuals with type I diabetes. Hum Immunol. 2002;63(1):61-70. Not sensitivity or specificity of an identified test. [pmid: 11916171].
Peng X, Zhang Y, Zhang H, et al. Interaction of tissue transglutaminase with nuclear transport protein importin-alpha3. Febs Letters. 1999;446(1):35-39. Not sensitivity or specificity of an identified test. [pmid: 10100610].
Pepper H W, Brandborg L L, Shanser J D, et al. Collagenous sprue. American Journal of Roentgenology, Radium Therapy, and Nuclear Medicine. 1974;121(2):275-282. Not sensitivity or specificity of an identified test.
Peraaho M, Kaukinen K, Paasikivi K, et al. Wheat-starch-based gluten-free products in the treatment of newly detected coeliac disease: prospective and randomized study. Alimentary Pharmacology & Therapeutics. 2003;17(4):587-594. Not sensitivity or specificity of an identified test. [pmid: 12622768].
Peracchi M, Bamonti-Catena F, Faggioli P, et al. Duodenal mucosa and extracellular cyclic nucleotide pattern in coeliac disease. Gut. 1993;34(6):769-773. Not sensitivity or specificity of an identified test. [pmid: 8100204]. [pmcid: 1374259].
Peracchi Maddalena, Trovato Cristina, Longhi Massimo, et al. Tissue transglutaminase antibodies in patients with end-stage heart failure. American Journal of Gastroenterology. 2002;97(11):2850-2854. Not sensitivity or specificity of an identified test. [pmid: 12425559].
Perdriger A. Do the HLA-DQ and DP genes play a role in rheumatoid arthritis?. Jt Bone Spine. 2001;68(1):12-18. Not sensitivity or specificity of an identified test.
Pereira R M, Yoshinari N H, De Oliveira R M, et al. Antiganglioside antibodies in patients with neuropsychiatric systemic lupus erythematosus. Lupus. 1992;1(3):175-179. Not sensitivity or specificity of an identified test. [pmid: 1301978].
Perera D R, Weinstein W M, Rubin C E. Symposium on pathology of the gastrointestinal tract-Part II. Small intestinal biopsy. Human Pathology. 1975;6(2):157-217. Not sensitivity or specificity of an identified test. [pmid: 50260].
Perez-Bravo F, Araya M, Mondragon A, et al. Genetic differences in HLA-DQA1* and DQB1* allelic distributions between celiac and control children in Santiago, Chile. Human Immunology. 1999;60(3):262-267. Improper control group. [pmid: 10321965].
Perez-Machado Miguel A, Ashwood Paul, Thomson Michael A, et al. Reduced transforming growth factor-beta1-producing T cells in the duodenal mucosa of children with food allergy. European Journal of Immunology. 2003;33(8):2307-2315. Not sensitivity or specificity of an identified test. [pmid: 12884306].
Peri A, Cowan B D, Bhartiya D, et al. Expression of Clara cell 10-kD gene in the human endometrium and its relationship to ovarian menstrual cycle. Dna and Cell Biology. 1994;13(5):495-503. Not sensitivity or specificity of an identified test. [pmid: 7517678].
Perichon B, Krishnamoorthy R. Asthma and HLA system. Allerg Immunol (Paris). 1991;23(7):301-307. Not sensitivity or specificity of an identified test. [pmid: 1741930].
Perisic V N, Kokai G. Coeliac disease and lymphangiectasia. Archives of Disease in Childhood. 1992;67(1):134-136. Not sensitivity or specificity of an identified test. [pmid: 1739329].
Perkkio M, Savilahti E, Kuitunen P. Semi-quantitative analysis of immunoglobulins and complement fractions 3 and 4 in the jejunal mucosa in coeliac disease and in food allergy in childhood. Immunohistochemical study by light and electron microscopy. Acta Pathologica Et Microbiologica Scandinavica. Section a, Pathology. 1981;89(4):343-350. Not sensitivity or specificity of an identified test.
Perri F, Pastore M, Festa V, et al. Intraduodenal lipase activity in celiac disease assessed by means of 13C mixed-triglyceride breath test. Journal of Pediatric Gastroenterology and Nutrition. 1998;27(4):407-410. Not sensitivity or specificity of an identified test. [pmid: 9779968].
Perrin Christophe, Baran Robert, Pisani Anne, et al. The onychomatricoma: additional histologic criteria and immunohistochemical study. American Journal of Dermatopathology. 2002;24(3):199-203. Not sensitivity or specificity of an identified test. [pmid: 12140434].
Perry A, Scheithauer B W, Nascimento A G. The immunophenotypic spectrum of meningeal hemangiopericytoma: a comparison with fibrous meningioma and solitary fibrous tumor of meninges. American Journal of Surgical Pathology. 1997;21(11):1354-1360. Not sensitivity or specificity of an identified test. [pmid: 9351573].
Persic M, Milin C, Varljen J, et al. Intestinal mucosa alkaline phosphatase in coeliac disease. Period Biol. 1992;94(2):121-126. Not sensitivity or specificity of an identified test.
Persliden J, Pettersson H B L, Falth-Magnusson K. Intestinal biopsy in children with coeliac disease; A Swedish national study of radiation dose and risk. Radiat Prot Dosim. 1995;57(14):459-462. Not sensitivity or specificity of an identified test.
Persliden J, Pettersson H B, Falth-Magnusson K. Radiation dose at small intestinal biopsies in children: results of a national study. Acta Paediatrica (Oslo, Norway - 1992). 1996;85(9):1042-1046. Not sensitivity or specificity of an identified test. [pmid: 8888915].
Persliden J, Petterson H B, Falth-Magnusson K. Small intestinal biopsy in children with coeliac disease: measurement of radiation dose and analysis of risk. Acta Paediatrica (Oslo, Norway - 1992). 1993;82(3):296-299. Not sensitivity or specificity of an identified test. [pmid: 8495087].
Persson B L, Stenberg P, Holmberg L, et al. Transamidating enzymes in maternal plasma and placenta in human pregnancies complicated by intrauterine growth retardation. Journal of Developmental Physiology. 1980;2(12):37-46. Not sensitivity or specificity of an identified test. [pmid: 6108341].
Perticarari S, Not T, Cauci S, et al. ELISA method for quantitative measurement of IgA and IgG specific anti-gliadin antibodies. Journal of Pediatric Gastroenterology and Nutrition. 1992;15(3):302-309. Not sensitivity or specificity of an identified test. [pmid: 1432469].
Perticarari S, Presani G, Trevisan M, et al. Serum IgA and IgG antibodies to alpha-gliadin: comparison between two ELISA methods. La Ricerca in Clinica E in Laboratorio. 1987;17(4):323-329. Not sensitivity or specificity of an identified test. [pmid: 3438667].
Perticarari S, Prodan M, Fragonas E, et al. CD69 expression on alpha-gliadin-specific T cells in coeliac disease. European Journal of Histochemistry - Ejh. 2002;46(1):13-22. Not sensitivity or specificity of an identified test. [pmid: 12044043].
Pertot W J, Sindres V, Szekeres G, et al. Model for quantitative immunohistochemical assessment of pulpal response to biomaterials. Journal of Biomedical Materials Research. 1997;34(4):457-462. Not sensitivity or specificity of an identified test. [pmid: 9054529].
Pertschuk L P, Cook A W, Gupta J K. Jejunal immunopathology in amyotrophic lateral sclerosis and multiple sclerosis. Identification of viral antigens by immunofluorescence. Lancet. 1977;1(8022):1119-1123. Not sensitivity or specificity of an identified test. [pmid: 69907].
Pervez S, Hasan S H, Aijaz F, et al. Changing patterns and re-distribution of antigen in poorly differentiated carcinomas: its implications in tumour diagnosis. Indian Journal of Pathology & Microbiology. 1998;41(1):55-66. Not sensitivity or specificity of an identified test. [pmid: 9581078].
Pesce G, Pesce F, Fiorino N, et al. Intraepithelial gamma/delta-positive T lymphocytest and intestinal villous atrophy. International Archives of Allergy and Immunology. 1996;110(3):233-237. Not sensitivity or specificity of an identified test. [pmid: 8688669].
Petaros P, Martelossi S, Tommasini A, et al. Prevalence of autoimmune disorders in relatives of patients with celiac disease. Digestive Diseases and Sciences. 2002;47(7):1427-1431. Not sensitivity or specificity of an identified test. [pmid: 12141796].
Peters M S, McEvoy M T. IgA antiendomysial antibodies in dermatitis herpetiformis. Journal of the American Academy of Dermatology. 1989;21(6):1225-1231. Not sensitivity or specificity of an identified test. [pmid: 2685059].
Peters T J, Doe W F, Heath J R, et al. Lysosomal acid hydrolase activity in intestinal biopsies from control subjects and patients with coeliac disease. Gut. 1973;14(5):430. Not sensitivity or specificity of an identified test. [pmid: 4716535].
Peters T J, Heath J R, Wansbrough-Jones M H, et al. Enzyme activities and properties of lysosomes and brush borders in jejunal biopsies from control subjects and patients with coeliac disease. Clinical Science and Molecular Medicine. 1975;48(4):259-267. Not sensitivity or specificity of an identified test. [pmid: 165030].
Peters T J, Jones P E, Wells G. Analytical subcellular fractionation of jejunal biopsy specimens: enzyme activities, organelle pathology and response to gluten withdrawal in patients with coeliac disease. Clinical Science and Molecular Medicine. 1978;55(3):285-292. Not sensitivity or specificity of an identified test. [pmid: 699505].
Peters T J, Jones P E, Jenkins W J, et al. Analytical subcellular fractionation of jejunal biopsy specimens: Enzyme activities, organelle pathology and response to corticosteroids in patients with non-responsive coeliac disease. Clin Sci Mol Med. 1978;55(3):293-300. Not sensitivity or specificity of an identified test. [pmid: 699505].
Petit E, Huber M, Rochat A, et al. Three novel point mutations in the keratinocyte transglutaminase (TGK) gene in lamellar ichthyosis: significance for mutant transcript level, TGK immunodetection and activity. European Journal of Human Genetics - Ejhg. 1997;5(4):218-228. Not sensitivity or specificity of an identified test. [pmid: 9359043].
Petronzelli F, Bonamico M, Ferrante P, et al. Genetic contribution of the HLA region to the familial clustering of coeliac disease. Annals of Human Genetics. 1997;61(Pt 4):307-317. Not sensitivity or specificity of an identified test. [pmid: 9365784].
Petronzelli F, Ferrante P, Triglione P, et al. Oligotyping of celiac multiplex families with the 11th International Histocompatibility Workshop reagents. Tissue Antigens. 1991;38(5):238-239. Improper control group. [pmid: 1780848].
Petronzelli F, Multari G, Ferrante P, et al. Different dose effect of HLA-DQ alpha beta heterodimers in insulin-dependent diabetes mellitus and celiac disease susceptibility. Human Immunology. 1993;36(3):156-162. Not sensitivity or specificity of an identified test. [pmid: 8320134].
Petrovsky N, Harrison L. HLA class II-associated polymorphism of interferon-gamma production implications for HLA-disease association. Hum Immunol. 1997;53(1):12-16. Not sensitivity or specificity of an identified test. [pmid: 9127142].
Pettersson A, Sjoberg K, Lernmark A, et al. HLA genotypes in coeliac disease and healthy individuals carrying gliadin antibodies. European Journal of Gastroenterology & Hepatology. 1993;5(6):445-450. Improper control group.
Pettifor J M. Letter: How different are we?. South African Medical Journal. Suid-Afrikaanse Tydskrif Vir Geneeskunde. 1974;48(16):669. Not sensitivity or specificity of an identified test. [pmid: 4823725].
Pettifor J M. Jejunal biopsy in the diagnosis of coeliac disease. S Afr Med J. 1974;48(16):669. Not sensitivity or specificity of an identified test. [pmid: 4823725].
Pham T H, Barr G D. Coeliac disease in adults. Presentation and management. Australian Family Physician. 1996;25(1):62-65. Not sensitivity or specificity of an identified test. [pmid: 8607777].
Phelan J J, Stevens F M, McNicholl B N. Chemical studies of gliadin toxicity. Ir J Med Sci. 1975;144(9):364. Not sensitivity or specificity of an identified test.
Phillips A D, Rice S J, France N E, et al. Small intestinal intraepithelial lymphocyte levels in cow's milk protein intolerance. Gut. 1979;20(6):509-512. Not sensitivity or specificity of an identified test. [pmid: 572802]. [pmcid: 1412463].
Phillips M A, Qin Q, Mehrpouyan M, et al. Keratinocyte transglutaminase membrane anchorage: analysis of site-directed mutants. Biochemistry. 1993;32(41):11057-11063. Not sensitivity or specificity of an identified test. [pmid: 8105889].
Phillips M A, Stewart B E, Qin Q, et al. Primary structure of keratinocyte transglutaminase. Proceedings of the National Academy of Sciences of the United Statest of America. 1990;87(23):9333-9337. Not sensitivity or specificity of an identified test.
Phillips S B, Kubilus J, Grassi A M, et al. The pancornulins: a group of basic low molecular weight proteins in mammalian epidermis and epithelium that may function as cornified envelope precursors. Comparative Biochemistry and Physiology. B, Comparative Biochemistry. 1990;95(4):781-788. Not sensitivity or specificity of an identified test.
Philotheou A. Epilogue: What have we learned to improve the treatment of children with diabetes mellitus and their families?. J Pediatr Endocrinol Metab. 2001;14(Suppl 1):697-700. Not sensitivity or specificity of an identified test. [pmid: 11393566].
Piacentini M. Tissue transglutaminase: a candidate effector element of physiological cell death. Current Topics in Microbiology and Immunology 1995;200163–175. Not sensitivity or specificity of an identified test
Piacentini M, Autuori F. Immunohistochemical localization of tissue transglutaminase and Bcl-2 in rat uterine tissues during embryo implantation and post-partum involution. Differentiation. 1994;57(1):51-61. Not sensitivity or specificity of an identified test. [pmid: 7915242].
Piacentini M, Colizzi V. Tissue transglutaminase: apoptosis versus autoimmunity. Immunology Today. 1999;20(3):130-134. Not sensitivity or specificity of an identified test. [pmid: 10203704].
Piacentini M, Melino G. Role of tissue transglutaminase in neuroblastoma cells undergoing apoptosis. Progress in Clinical and Biological Research 1994;385123–129. Not sensitivity or specificity of an identified test
Piacentini M, Annicchiarico-Petruzzelli M, Oliverio S, et al. Phenotype-specific “tissue” transglutaminase regulation in human neuroblastoma cells in response to retinoic acid: correlation with cell death by apoptosis. International Journal of Cancer. Journal International Du Cancer. 1992;52(2):271-278. Not sensitivity or specificity of an identified test. [pmid: 1381704].
Piacentini M, Autuori F, Dini L, et al. ‘Tissue’ transglutaminase is specifically expressed in neonatal rat liver cells undergoing apoptosis upon epidermal growth factor-stimulation. Cell Tissue Res. 1991;263(2):227-235. Not sensitivity or specificity of an identified test. [pmid: 1672508].
Piacentini M, Farrace M G, Hassan C, et al. ‘Tissue’ transglutaminase release from apoptotic cells into extracellular matrix during human liver fibrogenesis. Journal of Pathology. 1999;189(1):92-98. Not sensitivity or specificity of an identified test. [pmid: 10451494].
Piacentini M, Fesus L, Melino G. Multiple cell cycle access to the apoptotic death programme in human neuroblastoma cells. Febs Letters. 1993;320(2):150-154. Not sensitivity or specificity of an identified test. [pmid: 8096193].
Piacentini M, Fesus L, Farrace M G, et al. The expression of “tissue” transglutaminase in two human cancer cell lines is related with the programmed cell death (apoptosis). European Journal of Cell Biology. 1991;54(2):246-254. Not sensitivity or specificity of an identified test. [pmid: 1679009].
Piacentini M, Piredda L, Starace D, et al. Differential growth of N- and S-type human neuroblastoma cells xenografted into SCID mice. Correlation with apoptosis. J Pathol. 1996;180(4):415-422. Not sensitivity or specificity of an identified test. [pmid: 9014863].
Piacentini M, Rodolfo C, Farrace M G, et al. “Tissue” transglutaminase in animal development. International Journal of Developmental Biology. 2000;44(6 Spec No):655-662. Not sensitivity or specificity of an identified test. [pmid: 11061429].
Piacentini Mauro, Farrace Maria, Grazia Piredda, et al. Transglutaminase overexpression sensitizes neuronal cell lines to apoptosis by increasing mitochondrial membrane potential and cellular oxidative stress. Journal of Neurochemistry. 2002;81(5):1061-1072. Not sensitivity or specificity of an identified test. [pmid: 12065619].
Picarelli A, Di Tola M, Sabbatella L, et al. 31–43 amino acid sequence of the alpha-gliadin induces anti-endomysial antibody production during in vitro challenge. Scandinavian Journal of Gastroenterology. 1999;34(11):1099-1102. Not sensitivity or specificity of an identified test. [pmid: 10582760].
Picarelli A, Di Tola M, Sabbatella L, et al. Immunologic evidence of no harmful effect of oats in celiac disease. American Journal of Clinical Nutrition. 2001;74(1):137-140. Not sensitivity or specificity of an identified test. [pmid: 11451729].
Picarelli A, Di Tola M, Sabbatella L, et al. Identification of a new coeliac disease subgroup: antiendomysial and anti-transglutaminase antibodies of IgG class in the absence of selective IgA deficiency. Journal of Internal Medicine. 2001;249(2):181-188. Improper control group. [pmid: 11240848].
Picarelli A, Maiuri L, Frate A, et al. Production of antiendomysial antibodies after in-vitro gliadin challenge of small intestine biopsy samples from patients with coeliac disease. Lancet. 1996;348(9034):1065-1067. Not sensitivity or specificity of an identified test. [pmid: 8874458].
Picarelli A, Maiuri L, Mazzilli M C, et al. Gluten-sensitive disease with mild enteropathy. Gastroenterology. 1996;111(3):608-616. Not sensitivity or specificity of an identified test. [pmid: 8780564].
Picarelli A, Sabbatella L, Di Tola M, et al. Forty-eight hours of biopsy culture improve the sensitivity of the in vitro gliadin challenge in the diagnosis of celiac disease. Clinical Chemistry. 2001;47(10):1841-1843. Not sensitivity or specificity of an identified test. [pmid: 11568096].
Picarelli A, Triglione P, Mariani P, et al. Use of a threshold serum level of anti-gliadin antibodies improves diagnostic efficiency of the test in adult coeliac disease but is unreliable as a screening test. Italian Journal of Gastroenterology. 1996;28(2):70-75. Improper control group. [pmid: 8781997].
Picarelli Antonio, Sabbatella Luigi, Di Tola, et al. Antiendomysial antibody detection in fecal supernatants: in vivo proof that small bowel mucosa is the site of antiendomysial antibody production. American Journal of Gastroenterology. 2002;97(1):95-98. Not sensitivity or specificity of an identified test. [pmid: 11808976].
Pierard-Franchimont C, Arrese J E, Pierard G E. Immunohistochemical aspects of the link between Malassezia ovalis and seborrheic dermatitis. J Eur Acad Dermatol Venereol. 1995;4(1):14-19. Not sensitivity or specificity of an identified test.
Pierard-Franchimont C, Arrese J E, Nikkels A F, et al. Factor XIIIa-positive dendrocytes and proliferative activity of cutaneous cancers. Virchows Archiv - an International Journal of Pathology. 1996;429(1):43-48. Not sensitivity or specificity of an identified test. [pmid: 8865852].
Pierard-Franchimont C, Dosal F L, Estrada J A, et al. Cutaneous hamartoma with pagetoid cells. American Journal of Dermatopathology. 1991;13(2):158-161. Not sensitivity or specificity of an identified test. [pmid: 1851401].
Pierucci Alessandro, Fofi Claudia, Bartoli Benedetta, et al. Antiendomysial antibodies in Berger's disease. American Journal of Kidney Diseases - the Official Journal of the National Kidney Foundation. 2002;39(6):1176-1182. Not sensitivity or specificity of an identified test. [pmid: 12046028].
Pietroletti R, Bishop A E, Carlei F, et al. Gut endocrine cell population in coeliac disease estimated by immunocytochemistry using a monoclonal antibody to chromogranin. Gut. 1986;27(7):838-843. Not sensitivity or specificity of an identified test. [pmid: 3525339]. [pmcid: 1433562].
Pietroletti R, Castro M, Mariani P, et al. Prostanoids in jejunal biopsy specimens of celiac children with active disease and on challenge diet. Radioimmunologic evaluation. Scandinavian Journal of Gastroenterology. 1987;22(10):1181-1184. Not sensitivity or specificity of an identified test. [pmid: 3481115].
Pietzak M M, Thomas D W. Childhood malabsorption. Pediatr Rev. 2003;24(6):195-204. Not sensitivity or specificity of an identified test. [pmid: 12777611].
Pignata C, Troncone R, Monaco G, et al. Impaired suppressor activity in children affected by coeliac disease. Gut. 1985;26(3):285-290. Not sensitivity or specificity of an identified test. [pmid: 3156076]. [pmcid: 1432636].
Pileri S, Poggi S, Baglioni P et al. Histology and immunohistology of bone marrow biopsy in multiple myeloma. European Journal of Haematology.Supplementum 1989;5152–59. Not sensitivity or specificity of an identified test
Piper J M, Langer O, et al. Is lung maturation related to fetal growth in diabetic or hypertensive pregnancies?. European Journal of Obstetrics, Gynecology, and Reproductive Biology. 1993;51(1):15-19. Not sensitivity or specificity of an identified test. [pmid: 8282138].
Piper Justin L, Gray Gary M, Khosla Chaitan. High selectivity of human tissue transglutaminase for immunoactive gliadin peptides: implications for celiac sprue. Biochemistry. 2002;41(1):386-393. Not sensitivity or specificity of an identified test. [pmid: 11772038].
Piredda L, Farrace M G, Lo Bello M, et al. Identification of ‘tissue’ transglutaminase binding proteins in neural cells committed to apoptosis. Faseb Journal - Official Publication of the Federation of American Societies for Experimental Biology. 1999;13(2):355-364. Not sensitivity or specificity of an identified test.
Pirmohamed M, Lin K, Chadwick D, et al. TNFalpha promoter region gene polymorphisms in carbamazepine-hypersensitive patients. Neurology. 2001;56(7):890-896. Not sensitivity or specificity of an identified test. [pmid: 11294926].
Pisegma J R. A difficult diagnosis: When is irritable bowel syndrome really celiac disease?. Med Crossfire. 2002;4(10):46-47. Not sensitivity or specificity of an identified test.
Pittman F E, Pittman J C. A light and electron microscopic study of sigmoid colonic mucosa in adult celiac disease. Scandinavian Journal of Gastroenterology. 1966;1(1):21-27. Not sensitivity or specificity of an identified test. [pmid: 5914448].
Pittschieler K, Ladinser B. Coeliac disease: screened by a new strategy. Acta paediatrica (Oslo, Norway : 1992).Supplement. 1996;41242–45. Improper control group
Pittschieler K, Gentili L, Niederhofer H. Onset of coeliac disease: A prospective longitudinal study. Acta Paediatr Int J Paediatr. 2003;92(10):1149-1152. Not sensitivity or specificity of an identified test.
Pittschieler K, Ladinser B, Petell J K. Reactivity of gliadin and lectins with celiac intestinal mucosa. Pediatric Research. 1994;36(5):635-641. Not sensitivity or specificity of an identified test. [pmid: 7877884].
Pittschieler K, Reissigl H, Mengarda G. Celiac disease in two different population groups of South Tirol. Journal of Pediatric Gastroenterology and Nutrition. 1988;7(3):400-402. Not sensitivity or specificity of an identified test. [pmid: 3260280].
Placido R, Mancino G, Amendola A, et al. Apoptosis of human monocytes/macrophages in Mycobacterium tuberculosis infection. Journal of Pathology. 1997;181(1):31-38. Not sensitivity or specificity of an identified test. [pmid: 9072000].
Plenz A, Fritz P, Konig G, et al. Immunohistochemical detection of factor XIIIa and factor XIIIs in synovial membranes of patients with rheumatoid arthritis or osteoarthritis. Rheumatology International. 1996;16(1):29-36. Not sensitivity or specificity of an identified test. [pmid: 8783420].
Ploski R, Ascher H, Sollid L M. HLA genotypes and the increased incidence of coeliac disease in Sweden. Scandinavian Journal of Gastroenterology. 1996;31(11):1092-1097. Improper control group. [pmid: 8938902].
Ploski R, Ek J, Thorsby E, et al. On the HLA-DQ(alpha 1*0501, beta 1*0201)-associated susceptibility in celiac disease: a possible gene dosage effect of DQB1*0201. Tissue Antigens. 1993;41(4):173-177. Improper control group. [pmid: 8362409].
Pocecco M, Ventura A. Coeliac disease and insulin-dependent diabetes mellitus: a causal association?. Acta Paediatrica (Oslo, Norway - 1992). 1995;84(12):1432-1433. Not sensitivity or specificity of an identified test. [pmid: 8645965].
Pociot F, McDermott M F. Genetics of type 1 diabetes mellitus. Genes and Immunity. 2002;3(5):235-249. Not sensitivity or specificity of an identified test. [pmid: 12209358].
Poddar S, Davies J A. Induction of tissue transglutaminase by structural analogs of trans retinoic acid. Fed Proc 1985;44(3):No 2110Not sensitivity or specificity of an identified test
Poddar S, Hong W K, Thacher S M, et al. Retinoic acid suppression of squamous differentiation in human head-and-neck squamous carcinoma cells. International Journal of Cancer. Journal International Du Cancer. 1991;48(2):239-247. Not sensitivity or specificity of an identified test. [pmid: 1708365].
Poddar U. Celiac disease: clinical features and diagnostic criteria. Indian Journal of Pediatrics. 1999;66(1 Suppl):S21-S25. Not sensitivity or specificity of an identified test. [pmid: 11132464].
Podolsky D K, LaMont J T. So, where are all the celiacs?. Gastroenterology. 1999;116(2):237. Not sensitivity or specificity of an identified test.
Poelman J R, Netelenbos J C, Van Der, et al. Diabetes mellitus, diarrhoea and malabsorption. Neth J Med. 1975;18(6):297-306. Not sensitivity or specificity of an identified test.
Polak J M, Pearse A G E, Van Noorden S. Secretin cells in coeliac disease. Gut. 1973;14(11):870-874. Not sensitivity or specificity of an identified test. [pmid: 4586733]. [pmcid: 1412853].
Polakowska R R, Eddy R L, Shows T B, et al. Epidermal type I transglutaminase (TGM1) is assigned to human chromosome 14. Cytogenetics and Cell Genetics. 1991;56(2):105-107. Not sensitivity or specificity of an identified test. [pmid: 1672846].
Polakowska R R, Graf B A, Falciano V, et al. Transcription regulatory elements of the first intron control human transglutaminase type I gene expression in epidermal keratinocytes. Journal of Cellular Biochemistry. 1999;73(3):355-369. Not sensitivity or specificity of an identified test. [pmid: 10321835].
Polanco I. Clinical relevance of villous atrophy. Pediatric Allergy and Immunology - Official Publication of the European Society of Pediatric Allergy and Immunology. 2001;12(Suppl 14):47-50. Not sensitivity or specificity of an identified test. [pmid: 11380899].
Polanco I. Clinical relevance of villus atrophy. Pediatrika. 2001;21(10):23-26. Not sensitivity or specificity of an identified test.
Polanco I, Mearin M L, Larrauri J, et al. Effect of gluten supplementation in healthy siblings of children with celiac disease. Gastroenterology. 1987;92(3):678-681. Not sensitivity or specificity of an identified test. [pmid: 3817390].
Poley J R. The scanning electron microscope: how valuable in the evaluation of small bowel mucosal pathology in chronic childhood diarrhea?. Scanning Microscopy. 1991;5(4):1037-1062. Not sensitivity or specificity of an identified test. [pmid: 1822028].
Poley J R, Bhatia M, Welsh J D. Disaccharidase deficiency in infants with cow's milk protein intolerance. Response to treatment. Digestion. 1978;17(2):97-107. Not sensitivity or specificity of an identified test. [pmid: 627328].
Poljac caron, Gajinov Z, Belic caron, et al. MHC class II antigens in alopecia areata. Acta Dermatovenerol Alp Pannonica Adriat. 2002;11(2):55-58. Not sensitivity or specificity of an identified test.
Pollack S. Chronic fatigue syndrome and immune dysfunction: Cause or effect?. Isr Med Assoc J. 2002;4(11 SUPPL.):883-885. Not sensitivity or specificity of an identified test. [pmid: 12455171].
Pollock D J. The liver in coeliac disease. Histopathology. 1977;1(6):421-430. Not sensitivity or specificity of an identified test. [pmid: 210103].
Pollock D J, Nagle R E, Jeejeebhoy K N, et al. The effect on jejunal mucosa of withdrawing and adding dietary gluten in cases of idiopathic steatorrhoea. Gut. 1970;11(7):567-575. Not sensitivity or specificity of an identified test. [pmid: 5452045]. [pmcid: 1553080].
Polvi A, Arranz E, Fernandez-Arquero M, et al. HLA-DQ2-negative celiac disease in Finland and Spain. Human Immunology. 1998;59(3):169-175. Not sensitivity or specificity of an identified test. [pmid: 9548076].
Polvi A, Eland C, Koskimies S, et al. HLA DQ and DP in Finnish families with celiac disease. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1996;23(3):221-234. Improper control group. [pmid: 8803535].
Polvi A, Garden O A, Elwood C M, et al. Canine major histocompatibility complex genes DQA and DQB in Irish setter dogs. Tissue Antigens. 1997;49(3 Pt 1):236-243. Not sensitivity or specificity of an identified test. [pmid: 9098930].
Polvi A, Maki M, Partanen J. Celiac patients predominantly inherit HLA-DPB1*0101 positive haplotype from HLA-DQ2 homozygous parent. Human Immunology. 1997;53(2):156-158. Not sensitivity or specificity of an identified test. [pmid: 9129973].
Polvi A, Maki M, Collin P, et al. TNF microsatellite alleles a2 and b3 are not primarily associated with celiac disease in the Finnish population. Tissue Antigens. 1998;51(5):553-555. Not sensitivity or specificity of an identified test. [pmid: 9672155].
Poon E, Nixon R. Cutaneous spectrum of coeliac disease. Australas J Dermatol. 2001;42(2):136-138. Not sensitivity or specificity of an identified test. [pmid: 11309040].
Popat S, Hearle N, Bevan S, et al. Mutational analysis of CD28 in coeliac disease. Scandinavian Journal of Gastroenterology. 2002;37(5):536-539. Not sensitivity or specificity of an identified test. [pmid: 12059054].
Popat S, Hearle N, Hogberg L, et al. Variation in the CTLA4/CD28 gene region confers an increased risk of coeliac disease. Annals of Human Genetics. 2002;66(Pt 2):125-137. Not sensitivity or specificity of an identified test. [pmid: 12174216].
Popat S, Hearle N, Wixey J, et al. Analysis of the CTLA4 gene in Swedish coeliac disease patients. Scandinavian Journal of Gastroenterology. 2002;37(1):28-31. Improper control group. [pmid: 11843030].
Popat S, Hogberg L, McGuire S, et al. Germline mutations in TGM2 do not contribute to coeliac disease susceptibility in the Swedish population. European Journal of Gastroenterology & Hepatology. 2001;13(12):1477-1479. Not sensitivity or specificity of an identified test. [pmid: 11742196].
Potolicchio I, Santambrogio L, Strominger J L. Molecular interaction and enzymatic activity of macrophage migration inhibitory factor with immunorelevant peptides. J Biol Chem. 2003;278(33):30889-30895. Not sensitivity or specificity of an identified test. [pmid: 12740374].
Powis S H, Rosenberg W M, Hall M, et al. TAP1 and TAP2 polymorphism in coeliac disease. Immunogenetics. 1993;38(5):345-350. Not sensitivity or specificity of an identified test. [pmid: 8344720].
Pozler O, Parizek J, Chylkova V, et al. Immunological aspects of diagnosis of celiac sprue in children. Sbornik Vedeckych Praci Lekarske Fakulty Karlovy University V Hradci Kralove. 1989;32(2):169-233. Not sensitivity or specificity of an identified test. [pmid: 2604776].
Prasad S, Thomas P, Nicholas D S, et al. Adult endomysial antibody-negative coeliac disease and cigarette smoking. European Journal of Gastroenterology & Hepatology. 2001;13(6):667-671. Not sensitivity or specificity of an identified test. [pmid: 11434592].
Pratesi R, Gandolfi L, Friedman H, et al. Serum IgA antibodies from patients with coeliac disease react strongly with human brain blood-vessel structures. Scandinavian Journal of Gastroenterology. 1998;33(8):817-821. Not sensitivity or specificity of an identified test. [pmid: 9754728].
Pratesi R, Gandolfi L, Garcia S G, et al. Prevalence of coeliac disease: Unexplained age-related variation in the same population. Scandinavian Journal of Gastroenterology. 2003;38(7):747-750. Not sensitivity or specificity of an identified test. [pmid: 12889561].
Pratesi Riccardo, Gandolfi Lenora, Martins Rita C, et al. Is the prevalence of celiac disease increased among epileptic patients?. Arquivos De Neuro-Psiquiatria. 2003;61(2b):330-334. Not sensitivity or specificity of an identified test. [pmid: 12894262].
Prati D, Bardella M T, Peracchi M, et al. High frequency of anti-endomysial reactivity in candidates to heart transplant. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(1):39-43. Not sensitivity or specificity of an identified test. [pmid: 11926572].
Presani G, Perticarari S, Mangiarotti M A. Flow cytometric detection of anti-gliadin antibodies. Journal of Immunological Methods. 1989;119(2):197-202. Serology <1990. [pmid: 2656868].
Presland R B, Dale B A. Epithelial structural proteins of the skin and oral cavity: function in health and disease. Critical Reviews in Oral Biology and Medicine - an Official Publication of the American Association of Oral Biologists. 2000;11(4):383-408. Not sensitivity or specificity of an identified test. [pmid: 11132762].
Presotto F, Betterle C. Insulin-dependent diabetes mellitus: A constellation of autoimmune diseases. J Pediatr Endocrinol Metab. 1997;10(5):455-469. Not sensitivity or specificity of an identified test. [pmid: 9401901].
Price H L, Gazzard B G, Dawson A M. Steatorrhoea in the elderly. Br Med J. 1977;1(6076):1582-1584. Not sensitivity or specificity of an identified test. [pmid: 871673]. [pmcid: 1607318].
Price P, Witt C, Allcock R, et al. The genetic basis for the association of the 8.1 ancestral haplotype (A1, B8, DR3) with multiple immunopathological diseases. Immunol Rev. 1999;167(-):257-274. Not sensitivity or specificity of an identified test. [pmid: 10319267].
Prieto V G, Reed J A, Shea C R. Immunohistochemistry of dermatofibromas and benign fibrous histiocytomas. Journal of Cutaneous Pathology. 1995;22(4):336-341. Not sensitivity or specificity of an identified test. [pmid: 7499573].
Priglinger Siegfried G, May Christian A, Neubauer Aljoscha S, et al. Tissue transglutaminase as a modifying enzyme of the extracellular matrix in PVR membranes. Investigative Ophthalmology & Visual Science. 2003;44(1):355-364. Not sensitivity or specificity of an identified test. [pmid: 12506096].
Primignani M, Agape D, Ronchi G, et al. Prevalence of duodenal and jejunal lesions in dermatitis herpetiformis. La Ricerca in Clinica E in Laboratorio. 1987;17(3):243-249. Not sensitivity or specificity of an identified test. [pmid: 3671997].
Prince H E, Norman G L, Binder W L. Immunoglobulin A (IgA) deficiency and alternative celiac disease-associated antibodies in sera submitted to a reference laboratory for endomysial IgA testing. Clinical and Diagnostic Laboratory Immunology. 2000;7(2):192-196. Improper control group. [pmid: 10702491]. [pmcid: 95847].
Prisco A, Troncone R, Mazzarella G, et al. Identical T-cell receptor beta chain rearrangements are present in T cells infiltrating the jejunal mucosa of untreated celiac patients. Hum Immunol. 1997;55(1):22-33. Not sensitivity or specificity of an identified test. [pmid: 9328786].
Probst-Cousin S, Poremba C, Rickert C H, et al. Factor XIIIa expression in granulomatous lesions due to sarcoidosis or mycobacterial infection. Pathology, Research and Practice. 1997;193(1112):741-745. Not sensitivity or specificity of an identified test. [pmid: 9521505].
Provost T T, Talal N, Bias W, et al. Ro(SS-A) positive Sjogren's/lupus erythematosus (SC/LE) overlap patients are associated with the HLA-DR3 and/or DRw6 phenotypes. J Invest Dermatol. 1988;91(4):369-371. Not sensitivity or specificity of an identified test. [pmid: 3262691].
Pruessner H T. Detecting celiac disease in your patients. American Family Physician 1998;57(5): 1023–34, 1039 . Not sensitivity or specificity of an identified test
Przemioslo R T, Kontakou M, Nobili V, et al. Raised pro-inflammatory cytokines interleukin 6 and tumour necrosis factor alpha in coeliac disease mucosa detected by immunohistochemistry. Gut. 1994;35(10):1398-1403. Not sensitivity or specificity of an identified test. [pmid: 7959194]. [pmcid: 1375013].
Przemioslo R T, Lundin K E, Sollid L M, et al. Histological changes in small bowel mucosa induced by gliadin sensitive T lymphocytes can be blocked by anti-interferon gamma antibody. Gut. 1995;36(6):874-879. Not sensitivity or specificity of an identified test. [pmid: 7615276]. [pmcid: 1382625].
Przemioslo R, Wright N A, Elia G, et al. Analysis of crypt cell proliferation in coeliac disease using MI-B1 antibody shows an increase in growth fraction. Gut. 1995;36(1):22-27. Not sensitivity or specificity of an identified test. [pmid: 7890231]. [pmcid: 1382347].
Pueschel S M, Romano C, Failla P, et al. A prevalence study of celiac disease in persons with Down syndrome residing in the United States of America. Acta Paediatrica (Oslo, Norway - 1992). 1999;88(9):953-956. Not sensitivity or specificity of an identified test. [pmid: 10519335].
Pynnonen P, Isometsa E, Aalberg V, et al. Is coeliac disease prevalent among adolescent psychiatric patients?. Acta Paediatrica (Oslo, Norway - 1992). 2002;91(6):657-659. Not sensitivity or specificity of an identified test. [pmid: 12162597].
Qari F A. Clinical presentation of adult celiac disease in Western Saudi Arabia. Saudi Med J. 2002;23(12):1514-1517. Not sensitivity or specificity of an identified test. [pmid: 12518204].
Qiu L, Escalante C R, Aggarwal A K, et al. Monomeric midkine induces tumor cell proliferation in the absence of cell-surface proteoglycan binding. Biochemistry. 2000;39(20):5977-5987. Not sensitivity or specificity of an identified test. [pmid: 10821669].
Quarsten H, McAdam S N, Jensen T, et al. Staining of celiac disease-relevant T cells by peptide-DQ2 multimers. Journal of Immunology (Baltimore, Md.- 1950). 2001;167(9):4861-4868. Not sensitivity or specificity of an identified test. [pmid: 11673490].
Quarsten H, Molberg O, Fugger L, et al. HLA binding and T cell recognition of a tissue transglutaminase-modified gliadin epitope. European Journal of Immunology. 1999;29(8):2506-2514. Not sensitivity or specificity of an identified test. [pmid: 10458765].
Quarsten H, Paulsen G, Johansen B H, et al. The P9 pocket of HLA-DQ2 (non-Aspbeta57) has no particular preference for negatively charged anchor residues found in other type 1 diabetes-predisposing non-Aspbeta57 MHC class II molecules. International Immunology. 1998;10(8):1229-1236. Not sensitivity or specificity of an identified test. [pmid: 9723710].
Quisel Anna, Gill James M, Westerberg Dyanne. Guideline for diagnosis of celiac disease. Delaware Medical Journal. 2002;74(5):229-241. Not sensitivity or specificity of an identified test. [pmid: 12063834].
Rabsztyn A, Green P H, Berti I, et al. Macroamylasemia in patients with celiac disease. American Journal of Gastroenterology. 2001;96(4):1096-1100. Not sensitivity or specificity of an identified test. [pmid: 11316153].
Radek J T, Jeong J M, Murthy S N, et al. Affinity of human erythrocyte transglutaminase for a 42-kDa gelatin-binding fragment of human plasma fibronectin. Proceedings of the National Academy of Sciences of the United States of America. 1993;90(8):3152-3156. Not sensitivity or specificity of an identified test. [pmid: 8097314]. [pmcid: 46257].
Radisch T, Riechers R, Hertl M. The humanized SCID mouse model to study HLA class II-linked autoimmunity to desmoglein 3 in pemphigus vulgaris. Br J Dermatol. 2002;146(2):189-193. Not sensitivity or specificity of an identified test. [pmid: 11903226].
Raghunath M, Cankay R, Kubitscheck U, et al. Transglutaminase activity in the eye: cross-linking in epithelia and connective tissue structures. Investigative Ophthalmology & Visual Science. 1999;40(12):2780-2787. Not sensitivity or specificity of an identified test. [pmid: 10549636].
Raghunath M, Hennies H C, Velten F, et al. A novel in situ method for the detection of deficient transglutaminase activity in the skin. Archives of Dermatological Research. 1998;290(11):621-627. Not sensitivity or specificity of an identified test. [pmid: 9860283].
Raghunath M, Hopfner B, Aeschlimann D, et al. Cross-linking of the dermo-epidermal junction of skin regenerating from keratinocyte autografts. Anchoring fibrils are a target for tissue transglutaminase. Journal of Clinical Investigation. 1996;98(5):1174-1184. Not sensitivity or specificity of an identified test. [pmid: 8787681]. [pmcid: 507540].
Rajagopalan G, Kudva Y C, Chen L, et al. Autoimmune diabetes in HLA-DR3/DQ8 transgenic mice expressing the co-stimulatory molecule B7-1 in the beta cells of islets of Langerhans. Int Immunol. 2003;15(9):1035-1044. Not sensitivity or specificity of an identified test. [pmid: 12917255].
Rajagopalan G, Kudva Y C, Flavell R A, et al. Accelerated diabetes in rat insulin promoter-tumor necrosis factor-alpha transgenic nonobese diabetic mice lacking major histocompatibility class II molecules. Diabetes. 2003;52(2):342-347. Not sensitivity or specificity of an identified test. [pmid: 12540606].
Raju R, Marietta E, Vinasco J, et al. Cryptic determinants and promiscuous sequences on human acetylcholine receptor: HLA-dependent dichotomy in T-cell function. Hum Immunol. 2002;63(4):237-247. Not sensitivity or specificity of an identified test. [pmid: 12039405].
Ralph D J, Schwartz G, Moore W, et al. The genetic and bacteriological aspects of Peyronie's disease. J Urol. 1997;157(1):291-294. Not sensitivity or specificity of an identified test. [pmid: 8976282].
Ramos-Arroyo M A, Feijoo E, Sanchez-Valverde F, et al. Heat-shock protein 70–1 and HLA class II gene polymorphisms associated with celiac disease susceptibility in Navarra (Spain). Human Immunology. 2001;62(8):821-825. Not sensitivity or specificity of an identified test. [pmid: 11476906].
Ransford Rupert A J, Hayes Mark, Palmer Martin, et al. A controlled, prospective screening study of celiac disease presenting as iron deficiency anemia. Journal of Clinical Gastroenterology. 2002;35(3):228-233. Not sensitivity or specificity of an identified test. [pmid: 12192198].
Rantala I, Maki M, Laasonen A, et al. Periodate-lysine-paraformaldehyde as fixative for the study of duodenal mucosa. Morphologic and immunohistochemical results at light and electron microscopic levels. Acta Pathologica, Microbiologica, Et Immunologica Scandinavica. Section a, Pathology. 1985;93(4):165-173. Not sensitivity or specificity of an identified test.
Rapoport M J, Bistritzer T, Vardi O, et al. Increased prevalence of diabetes-related autoantibodies in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1996;23(5):524-527. Not sensitivity or specificity of an identified test. [pmid: 8985839].
Ratanachaiyavong S, McGregor A M. HLA-DPB1 polymorphisms on the MHC-extended haplotypes of families of patients with Graves' disease: Two distinct HLA-DR17 haplotypes. Eur J Clin Invest. 1994;24(5):309-315. Not sensitivity or specificity of an identified test. [pmid: 8088306].
Rautonen J, Rautonen N, Savilahti E. Antibodies to gliadin in children with coeliac disease. Acta Paediatrica Scandinavica. 1991;80(12):1200-1206. Improper control group. [pmid: 1785292].
Rautonen N, Rautonen J, Savilahti E. Influence of the G2m(n) allotype and age on IgG subclass distribution in antibodies to dietary proteins in children with coeliac disease. Clinical and Experimental Immunology. 1990;81(2):306-310. Not sensitivity or specificity of an identified test. [pmid: 2117511]. [pmcid: 1535049].
Ravaglia Giovanni, Forti Paola, Maioli Fabiola, et al. Increased prevalence of coeliac disease in autoimmune thyroiditis is restricted to aged patients. Experimental Gerontology. 2003;38(5):589-595. Not sensitivity or specificity of an identified test. [pmid: 12742537].
Ravelli A M, Tobanelli P, Minelli L, et al. Endoscopic features of celiac disease in children. Gastrointestinal Endoscopy. 2001;54(6):736-742. Not sensitivity or specificity of an identified test. [pmid: 11726850].
Rawashdeh M O, Abu-Farsakh N, Al Jaberi T M. Paediatric upper gastro-intestinal endoscopy in developing countries. Ann Trop Paediatr. 1996;16(4):341-346. Not sensitivity or specificity of an identified test. [pmid: 8985532].
Rawlings J M, Lucas M L, Russell R I. Measurement of jejunal surface pH in situ by plastic pH electrode in patients with coeliac disease. Scandinavian Journal of Gastroenterology. 1987;22(3):377-384. Not sensitivity or specificity of an identified test. [pmid: 3589505].
Read M, O'Halloran E T, O'sullivan C. Coeliac disease in adolescents/young adults: Difficulties in monitoring. Br J Biomed Sci. 2000;57(3):217-221. Not sensitivity or specificity of an identified test. [pmid: 11050774].
Redondo M J, Eisenbarth G S. Genetic control of autoimmunity in Type I diabetes and associated disorders. Diabetologia. 2002;45(5):605-622. Not sensitivity or specificity of an identified test. [pmid: 12107741].
Redondo M J, Rewers M, Yu L, et al. Genetic determination of islet cell autoimmunity in monozygotic twin, dizygotic twin, and non-twin siblings of patients with type 1 diabetes: prospective twin study. Bmj (Clinical Research Ed.). 1999;318(7185):698-702. Not sensitivity or specificity of an identified test. [pmid: 10074012].
Redondo M J, Yu L, Hawa M, et al. Heterogeneity of type I diabetes: analysis of monozygotic twins in Great Britain and the United States. Diabetologia. 2001;44(3):354-362. Not sensitivity or specificity of an identified test. [pmid: 11317668].
Reen D J, O'Regan D. HLA antigen frequencies in an Irish population. Tissue Antigens. 1980;15(4):369-372. Not sensitivity or specificity of an identified test. [pmid: 7466782].
Reeves G E, Burns C, Hall S T, et al. The measurement of IgA and IgG transglutaminase antibodies in celiac disease: a comparison with current diagnostic methods. Pathology. 2000;32(3):181-185. Improper control group. [pmid: 10968391].
Regan P T, DiMagno E P. Exocrine pancreatic insufficiency in celiac sprue: A cause of treatment failure. Gastroenterology. 1980;78(3):484-487. Not sensitivity or specificity of an identified test. [pmid: 7351287].
Regezi J A, Nickoloff B J, Headington J T. Oral submucosal dendrocytes: factor XIIIa+ and CD34+ dendritic cell populations in normal tissue and fibrovascular lesions. Journal of Cutaneous Pathology. 1992;19(5):398-406. Not sensitivity or specificity of an identified test. [pmid: 1282135].
Regezi J A, Zarbo R J, Daniels T E, et al. Oral traumatic granuloma. Characterization of the cellular infiltrate. Oral Surgery, Oral Medicine, and Oral Pathology. 1993;75(6):723-727. Not sensitivity or specificity of an identified test. [pmid: 8100057].
Regnier M, Desbas C, Bailly C, et al. Differentiation of normal and tumoral human keratinocytes cultured on dermis: reconstruction of either normal or tumoral architecture. In Vitro Cellular & Developmental Biology - Journal of the Tissue Culture Association. 1988;24(7):625-632. Not sensitivity or specificity of an identified test. [pmid: 2456282].
Reibel J, Clausen H, Dale B A et al. Immunohistochemical analysis of stratum corneum components in oral squamous epithelia. Differentiation 1989;Research in Biological Diversity; 41(3):237–244. Not sensitivity or specificity of an identified test
Reichrath J, Rafi L, Muller S M, et al. Immunohistochemical analysis of 1,25-dihydroxyvitamin D3 receptor in cervical carcinoma. Histochemical Journal. 1998;30(8):561-567. Not sensitivity or specificity of an identified test. [pmid: 9792274].
Reichstetter S, Kwok W W, Nepom G T. Impaired binding of a DQ2 and DQ8-binding HSV VP16 peptide to a DQA1*0501/DQB1*0302 trans class II heterodimer. Tissue Antigens. 1999;53(1):101-105. Not sensitivity or specificity of an identified test. [pmid: 10082436].
Reichstetter S, Kwok W W, Kochik S, et al. MHC-peptide ligand interactions establish a functional threshold for antigen-specific T cell recognition. Hum Immunol. 1999;60(7):608-618. Not sensitivity or specificity of an identified test. [pmid: 10426278].
Reifen R, Buskila D, Maislos M, et al. Serum prolactin in coeliac disease: A marker for disease activity. Arch Dis Child. 1997;77(2):155-157. Not sensitivity or specificity of an identified test. [pmid: 9301358].
Reifen R, Reif S, Buskila D, et al. Transthyretin: a marker for celiac disease activity. Journal of Medicine. 1998;29(12):30-36. Not sensitivity or specificity of an identified test. [pmid: 9704290].
Reijonen H, Ilonen J, Knip M, et al. Insulin-dependent diabetes mellitus associated with dermatitis herpetiformis: evidence for heterogeneity of HLA-associated genes. Tissue Antigens. 1991;37(2):94-96. Not sensitivity or specificity of an identified test. [pmid: 2057939].
Reims A, Redfors S, Ascher H, et al. Electrogenic ion transport in duodenal biopsies from children with coeliac disease. Scandinavian Journal of Gastroenterology. 2002;37(1):43-50. Not sensitivity or specificity of an identified test. [pmid: 11843034].
Reina J, Ballesteros F, Gasco J, et al. Usefulness of pp65 antigenemia and viremia in the follow-up of renal transplant recipients with cytomegalovirus disease treated with ganciclovir. Diagnostic Microbiology and Infectious Disease. 2000;37(2):83-86. Not sensitivity or specificity of an identified test. [pmid: 10863101].
Rensch M J, Merenich J A, Lieberman M, et al. Gluten-sensitive enteropathy in patients with insulin-dependent diabetes mellitus. Annals of Internal Medicine. 1996;124(6):564-567. Not sensitivity or specificity of an identified test. [pmid: 8597319].
Rensch M J, Szyjkowski R, Shaffer R T, et al. The prevalence of celiac disease autoantibodies in patients with systemic lupus erythematosus. American Journal of Gastroenterology. 2001;96(4):1113-1115. Not sensitivity or specificity of an identified test. [pmid: 11316156].
Rettenbacher T, Hollerweger A, Macheiner P, et al. Adult celiac disease: US signs. Radiology. 1999;211(2):389-394. Not sensitivity or specificity of an identified test. [pmid: 10228518].
Reunala T. Dermatitis herpetiformis: coeliac disease of the skin. Annals of Medicine. 1998;30(5):416-418. Not sensitivity or specificity of an identified test. [pmid: 9814827].
Reunala T. Incidence of familial dermatitis herpetiformis. Br J Dermatol. 1996;134(3):394-398. Not sensitivity or specificity of an identified test. [pmid: 8731659].
Reunala T, Chorzelski T P, Viander M, et al. IgA anti-endomysial antibodies in dermatitis herpetiformis: correlation with jejunal morphology, gluten-free diet and anti-gliadin antibodies. British Journal of Dermatology. 1987;117(2):185-191. Not sensitivity or specificity of an identified test. [pmid: 3651340].
Reunala T, Collin P, Holm K, et al. Tolerance to oats in dermatitis herpetiformis. Gut. 1998;43(4):490-493. Not sensitivity or specificity of an identified test. [pmid: 9824575]. [pmcid: 1727274].
Reunala T, Helin H, Pasternack A, et al. Renal involvement and circulating immune complexes in dermatitis herpetiformis. Journal of the American Academy of Dermatology. 1983;9(2):219-223. Not sensitivity or specificity of an identified test. [pmid: 6886113].
Reunala T, Salmi J, Karvonen J. Dermatitis herpetiformis and celiac disease associated with Addison's disease. Archives of Dermatology. 1987;123(7):930-932. Not sensitivity or specificity of an identified test. [pmid: 3606172].
Reunala T, Salo O P, Tiilikainen A, et al. Histocompatibility antigens and dermatitis herpetiformis with special reference to jejunal abnormalities and acetylator phenotype. Br J Dermatol. 1976;94(2):139-143. Not sensitivity or specificity of an identified test. [pmid: 1252348].
Reunala T, Salo O P, Tiilikainen A, et al. Family studies in dermatitis herpetiformis. Annals of Clinical Research. 1976;8(4):254-261. Not sensitivity or specificity of an identified test. [pmid: 999211].
Reynolds N J, Todd C, Angus B. Overexpression of protein kinase C-alpha and -beta isozymes by stromal dendritic cells in basal and squamous cell carcinoma. British Journal of Dermatology. 1997;136(5):666-673. Not sensitivity or specificity of an identified test. [pmid: 9205496].
Rhyner C, Weichel M, Hubner P, et al. Phage display of human antibodies from a patient suffering from coeliac disease and selection of isotype-specific scFv against gliadin. Immunology. 2003;110(2):269-274. Not sensitivity or specificity of an identified test. [pmid: 14511241]. [pmcid: 1783043].
Ribes C, Pena A S, Pereda A, et al. IGA gliadin antibodies, a useful screening test for coeliac disease in family members of children with coeliac disease. J Clin Nutr Gastroenterol. 1991;6(4):196-202. Not sensitivity or specificity of an identified test.
Ribes Koninckx C, Pereda Perez R A, Ferrer Calvete J, et al. The value of the measurement of IgA antigliadin antibodies in a pediatric unit in Spain. A prospective study. J Clin Nutr Gastroenterol. 1986;1(1):26-29. Not sensitivity or specificity of an identified test.
Ribes-Koninckx C, Alfonso P, Ortigosa L, et al. A beta-turn rich oats peptide as an antigen in an ELISA method for the screening of coeliac disease in a paediatric population. European Journal of Clinical Investigation. 2000;30(8):702-708. Improper control group. [pmid: 10964162].
Riccabona M, Rossipal E. Sonographic findings in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1993;17(2):198-200. Not sensitivity or specificity of an identified test. [pmid: 8229548].
Rice R H, Green H. Presence in human epidermal cells of a soluble protein precursor of the cross-linked envelope: activation of the cross-linking by calcium ions. Cell. 1979;18(3):681-694. Not sensitivity or specificity of an identified test. [pmid: 42494].
Rice R H, Mehrpouyan M, O'Callahan W, et al. Keratinocyte transglutaminase: differentiation marker and member of an extended family. Epithelial Cell Biology. 1992;1(3):128-137. Not sensitivity or specificity of an identified test. [pmid: 1364041].
Richiardi P, Borelli I, Malavasi F, et al. HLA antigens in juvenile dermatitis herpetiformis. Acta Dermato-Venereologica. 1981;61(3):241-244. Not sensitivity or specificity of an identified test. [pmid: 6167108].
Richter K H, Schnapke R, Clauss M, et al. Epidermal Ginf 1-chalone and transforming growth factor-beta are two different endogenous inhibitors of epidermal cell proliferation. J Cell Physiol. 1990;142(3):496-504. Not sensitivity or specificity of an identified test. [pmid: 1968903].
Riecken E O, Martini G A. The classification of abnormal small intestinal mucosal appearances. Morphology, function and diagnostic significance. German Medicine. 1973;3(34):120-127. Not sensitivity or specificity of an identified test. [pmid: 4607727].
Riecken E O, Sahlfeld M, Lorenz-Meyer H. [Quantification of the three-dimensional structure of jejunal mucosa in healthy subjects and patients with coeliac disease (author's transl)]: Quantitative Untersuchungen zur dreidimensionalen Struktur der Dunndarmschleimhaut bei Besunden und Patienten mit einheimischer Sprue. Deutsche Medizinische Wochenschrift. 1976;101(2):51-53. Not sensitivity or specificity of an identified test. [pmid: 1245156].
Riedy M C, Muirhead K A, Jensen C P, et al. Use of a photolabeling technique to identify nonviable cells in fixed homologous or heterologous cell populations. Cytometry - the Journal of the Society for Analytical Cytology. 1991;12(2):133-139. Not sensitivity or specificity of an identified test. [pmid: 2049970].
Riestra S, Fernandez E, Rodrigo L, et al. Prevalence of Coeliac disease in the general population of northern Spain. Strategies of serologic screening. Scandinavian Journal of Gastroenterology. 2000;35(4):398-402. Not sensitivity or specificity of an identified test. [pmid: 10831263].
Rihs H-P, Chen Z, Cremer R, et al. HLA class II antigens DR4 and DQ8 are associated with allergy to hevein, a major allergen of Hevea latex. Tissue Antigens. 1997;49(1):92-95. Not sensitivity or specificity of an identified test. [pmid: 9027975].
Rihs H-P, Chen Z, Rueff F, et al. HLA-DQ8 and the HLA-DQ8-DR4 haplotype are positively associated with the hevein-specific IgE immune response in health care workers with latex allergy. J Allergy Clin Immunol. 2002;110(3):507-514. Not sensitivity or specificity of an identified test. [pmid: 12209103].
Rihs H-P, Cremer R, Chen Z, et al. Molecular analysis of DRB and DQB 1 alleles in German spina bifida patients with and without IgE responsiveness to the latex major allergen Hev b 1. Clin Exp Allergy. 1998;28(2):175-180. Not sensitivity or specificity of an identified test. [pmid: 9515590].
Rinas U, Risse B, Jaenicke R, et al. Characterization of recombinant factor XIIIa produced in Saccharomyces cerevisiae. Bio/Technology (Nature Publishing Company). 1990;8(6):543-546. Not sensitivity or specificity of an identified test. [pmid: 1369439].
Riordan S M, McIver C J, Wakefield D, et al. Luminal antigliadin antibodies in small intestinal bacterial overgrowth. American Journal of Gastroenterology. 1997;92(8):1335-1338. Not sensitivity or specificity of an identified test. [pmid: 9260801].
Risch N. Assessing the role of HLA-linked and unlinked determinants of disease. American Journal of Human Genetics. 1987;40(1):1-14. Not sensitivity or specificity of an identified test. [pmid: 3618593]. [pmcid: 1684002].
Rischmueller M, Lester S, Chen Z, et al. HLA class II phenotype controls diversification of the autoantibody response in primary Sjogren's syndrome (pSS). Clinical and Experimental Immunology. 1998;111(2):365-371. Not sensitivity or specificity of an identified test. [pmid: 9486405]. [pmcid: 1904917].
Risdon R A, Keeling J W. Quantitation of the histological changes found in small intestinal biopsy specimens from children with suspected coeliac disease. Gut. 1974;15(1):9-18. Unable to extract data. [pmid: 4820632]. [pmcid: 1412946].
Risdon R A, Meinhard E A, Wadbrook D G, et al. Small intestinal biopsy in childhood coeliac disease. Postgraduate Medical Journal. 1975;51(600):716-721. Not sensitivity or specificity of an identified test. [pmid: 1105506].
Ritter S J, Davies P J. Identification of a transforming growth factor-beta1/bone morphogenetic protein 4 (TGF-beta1/BMP4) response element within the mouse tissue transglutaminase gene promoter. Journal of Biological Chemistry. 1998;273(21):12798-12806. Not sensitivity or specificity of an identified test. [pmid: 9582307].
Rittmaster R S, Norman R W, Thomas L N, et al. Evidence for atrophy and apoptosis in the prostates of men given finasteride. Journal of Clinical Endocrinology and Metabolism. 1996;81(2):814-819. Not sensitivity or specificity of an identified test. [pmid: 8636309].
Rittmaster R S, Thomas L N, Wright A S, et al. The utility of tissue transglutaminase as a marker of apoptosis during treatment and progression of prostate cancer. Journal of Urology. 1999;162(6):2165-2169. Not sensitivity or specificity of an identified test. [pmid: 10569613].
Rittner C, DeMarchi M, Mollenhauer E, et al. Coeliac disease and C4A*QO: an association secondary to HLA-DR3. Tissue Antigens. 1984;23(2):130-134. Not sensitivity or specificity of an identified test. [pmid: 6608806].
Robards M F. Changes in plasma nephelometry after oral fat loading in children with normal and abnormal small intestinal morphology. Archives of Disease in Childhood. 1975;50(8):631-636. Not sensitivity or specificity of an identified test. [pmid: 1200679].
Robert M E, Ament M E, Weinstein W M. The histologic spectrum and clinical outcome of refractory and unclassified sprue. American Journal of Surgical Pathology. 2000;24(5):676-687. Unable to extract data. [pmid: 10800986].
Roberts C, Jack F, Angus B, et al. Immunohistochemical detection of CD30 remains negative in nodular lymphocyte-predominant Hodgkin's disease using enhanced antigen retrieval. Histopathology. 2002;40(2):166-170. Not sensitivity or specificity of an identified test. [pmid: 11952861].
Roberts I M. Workup of the patient with malabsorption. Postgraduate Medicine 1987;81(7):32–3, 37. Not sensitivity or specificity of an identified test
Roberts R K, Campbell C B, Bryant S J, et al. Xylose-1-sup 1sup 4C absorption test: the use of urine, serum and breath analysis, and comparison with a colorimetric assay. Australian and New Zealand Journal of Medicine. 1976;6(6):532-536. Not sensitivity or specificity of an identified test. [pmid: 1071535].
Roberts S H, Heffernan C, Douglas A P. The sialic acid and carbohydrate content and the synthesis of glycoprotein from radioactive precursors by tissues of the normal and diseases upper intestinal tract. Clinica Chimica Acta 1975;International Journal of Clinical Chemistry; 63(2):121–128. Not sensitivity or specificity of an identified test
Roberts-Thomson I C, Stevens D P, Michel B. Factors influencing small bowel changes in dermatitis herpetiformis. Australian and New Zealand Journal of Medicine. 1977;7(4):356-362. Not sensitivity or specificity of an identified test. [pmid: 270984].
Robertson D A, Bullen A, Field H, et al. Suppressor cell activity, splenic function and HLA B8 status in man. Journal of Clinical & Laboratory Immunology. 1982;9(2):133-138. Not sensitivity or specificity of an identified test. [pmid: 6218306].
Robinson B N, Roberts D F, Mather B A, et al. Coeliac disease and HLA: a family study. Journal of Immunogenetics. 1980;7(5):381-391. Not sensitivity or specificity of an identified test. [pmid: 7430678].
Robinson D C, Watson A J, Wyatt E H, et al. Incidence of small-intestinal mucosal abnormalities and of clinical coeliac disease in the relatives of children with coeliac disease. Gut. 1971;12(10):789-793. Not sensitivity or specificity of an identified test. [pmid: 5123275]. [pmcid: 1411884].
Robinson T J, Nelson S D, Haire M, et al. Jejunal villous changes associated with farmer's lung. Postgraduate Medical Journal. 1981;57(673):697-701. Not sensitivity or specificity of an identified test. [pmid: 7339601].
Robles David T, Fain Pamela R, Gottlieb Peter A et al. The genetics of autoimmune polyendocrine syndrome type II. Endocrinology and Metabolism Clinics of North America 2002;31(2):353–68, Vi. Not sensitivity or specificity of an identified test
Roch A M, Noel P, el Alaoui S, et al. Differential expression of isopeptide bonds N epsilon (gamma-glutamyl) lysine in benign and malignant human breast lesions: an immunohistochemical study. International Journal of Cancer. Journal International Du Cancer. 1991;48(2):215-220. Not sensitivity or specificity of an identified test. [pmid: 1673451].
Rodriguez-Soriano J, Arrieta A, Vallo A, et al. IgA antigliadin antibodies in children with IgA mesangial glomerulonephritis. Lancet. 1988;1(8594):1109-1110. Not sensitivity or specificity of an identified test. [pmid: 2896938].
Roep B O, Bontrop R E, Pena A S, et al. An HLA-DQ alpha allele identified at DNA and protein level is strongly associated with celiac disease. Hum Immunol. 1988;23(4):271-279. Not sensitivity or specificity of an identified test. [pmid: 2906922].
Roger M. Influence of host genes on HIV-1 disease progression. Faseb J. 1998;12(9):625-632. Not sensitivity or specificity of an identified test. [pmid: 9619442].
Rogers A I. Steatorrhea. Postgraduate Medicine. 1971;50(6):123-129. Not sensitivity or specificity of an identified test. [pmid: 5128036].
Roggini M, Bonamico M, Capocaccia P et al. Radiological changes of the ileum in children with coeliac disease: is “intestinal adaptation” a specific radiographic sign?. Rivista Europea Per Le Scienze Mediche E Farmacologiche = European Review for Medical and Pharmacological Sciences = Revue Europeenne Pour Les Sciences Medicales Et Pharmacologiques 1990;12(3):159–164. Not sensitivity or specificity of an identified test
Rognum T O, Kett K, Fausa O, et al. Raised number of jejunal IgG2-producing cells in untreated adult coeliac disease compared with food allergy. Gut. 1989;30(11):1574-1580. Not sensitivity or specificity of an identified test. [pmid: 2599444]. [pmcid: 1434337].
Rokkas T, Vaja S, Murphy G M, et al. Postheparin plasma diamine oxidase in health and intestinal disease. Gastroenterology. 1990;98(6):1493-1501. Not sensitivity or specificity of an identified test. [pmid: 2110916].
Roldan M B, Barrio R, Roy G, et al. Diagnostic value of serological markers for celiac disease in diabetic children and adolescents. Journal of Pediatric Endocrinology & Metabolism - Jpem. 1998;11(6):751-756. Improper control group. [pmid: 9829231].
Rollason T P, Byrne P, Williams A, et al. Expression of epithelial membrane and 3-fucosyl-N-acetyllactosamine antigens in cervix uteri with particular reference to adenocarcinoma in situ. Journal of Clinical Pathology. 1988;41(5):547-552. Not sensitivity or specificity of an identified test. [pmid: 3384986]. [pmcid: 1141509].
Rolles C J. Proceedings: Usefulness of a modified D-xylose absorption test in the preliminary diagnosis of coeliac disease and its later confirmation. Archives of Disease in Childhood 1973;48(10):825Not sensitivity or specificity of an identified test
Rolles C J, McNeish A S. Standardised approach to gluten challenge in diagnosing childhood coeliac disease. British Medical Journal. 1976;1(6021):1309-1311. Not sensitivity or specificity of an identified test. [pmid: 1268678]. [pmcid: 1640359].
Rolles C J, Anderson M, McNeish A S. Confirming persistence of gluten intolerance in children diagnosed as having coeliac disease in infancy. Archives of Disease in Childhood. 1975;50(4):259-263. Not sensitivity or specificity of an identified test. [pmid: 1147665].
Rolles C J, Nutter S, Kendall M J, et al. One-hour blood-xylose screening-test for coeliac disease in infants and young children. Lancet. 1973;2(7837):1043-1045. Not sensitivity or specificity of an identified test. [pmid: 4127308].
Romaldini Ceres C, Barbieri Dorina, Okay Thelma S, et al. Serum soluble interleukin-2 receptor, interleukin-6, and tumor necrosis factor-alpha levels in children with celiac disease: response to treatment. Journal of Pediatric Gastroenterology and Nutrition. 2002;35(4):513-517. Not sensitivity or specificity of an identified test. [pmid: 12394376].
Romano Corrado, Pettinato Rosa, Ragusa Letizia, et al. Is there a relationship between zinc and the peculiar comorbidities of Down syndrome?. Down Syndrome, Research and Practice - the Journal of the Sarah Duffen Centre / University of Portsmouth. 2002;8(1):25-28. Not sensitivity or specificity of an identified test.
Ronningen K S. Genetics in the prediction of insulin-dependent diabetes mellitus: from theory to practice. Annals of Medicine. 1997;29(5):387-392. Not sensitivity or specificity of an identified test. [pmid: 9453285].
Ronningen K S, Keiding N, Green A. Correlations between the incidence of childhood-onset type I diabetes in Europe and HLA genotypes. Diabetologia. 2001;44(Suppl 3):b51-b59. Not sensitivity or specificity of an identified test. [pmid: 11724418].
Ronningen K S, Undlien D E, Ploski R, et al. Linkage disequilibrium between TAP2 variants and HLA class II alleles; no primary association between TAP2 variants and insulin-dependent diabetes mellitus. European Journal of Immunology. 1993;23(5):1050-1056. Not sensitivity or specificity of an identified test. [pmid: 8477801].
Rood J J, Hooff J P, Keuning J J. Disease predisposition, immune responsiveness and the fine structure of the HL-A supergene. A need for a reappraisal. Transplantation Reviews 1975;2275–104. Not sensitivity or specificity of an identified test
Rorke E A, Jacobberger J W. Transforming growth factor-beta 1 (TGF beta 1) enhances apoptosis in human papillomavirus type 16-immortalized human ectocervical epithelial cells. Experimental Cell Research. 1995;216(1):65-72. Not sensitivity or specificity of an identified test. [pmid: 7556448].
Rosa Utiyama S R, Silva Kotze L M, Nisihara R M, et al. Spectrum of autoantibodies in celiac patients and relatives. Digestive Diseases and Sciences. 2001;46(12):2624-2630. Not sensitivity or specificity of an identified test. [pmid: 11768251].
Rosales J L, Isseroff R R. Increased expression of a high molecular weight (130 KD) protein kinase C isoform in a differentiation-defective ras-transfected keratinocyte line. Journal of Cellular Physiology. 1995;164(3):509-521. Not sensitivity or specificity of an identified test. [pmid: 7544354].
Rosch T. Small-bowel endoscopy. Endoscopy. 2002;34(11):896-899. Not sensitivity or specificity of an identified test. [pmid: 12430074].
Roschmann E, Wienker T F, Volk B A. Role of T cell receptor delta gene in susceptibility to celiac disease. Journal of Molecular Medicine (Berlin, Germany). 1996;74(2):93-98. Not sensitivity or specificity of an identified test. [pmid: 8820404].
Roschmann E, Wienker T F, Gerok W, et al. T-cell receptor variable genes and genetic susceptibility to celiac disease: an association and linkage study. Gastroenterology. 1993;105(6):1790-1796. Not sensitivity or specificity of an identified test. [pmid: 8253354].
Roschmann E, Wienker T F, Gerok W, et al. Analysis of marker genes contributing to coeliac disease susceptibility. Advances in Experimental Medicine and Biology. 1995;371b:1339-1343. Not sensitivity or specificity of an identified test. [pmid: 7502813].
Rosdy M, Clauss L C. Terminal epidermal differentiation of human keratinocytes grown in chemically defined medium on inert filter substrates at the air-liquid interface. Journal of Investigative Dermatology. 1990;95(4):409-414. Not sensitivity or specificity of an identified test. [pmid: 1698886].
Rose C, Dieterich W, Brocker E B, et al. Circulating autoantibodies to tissue transglutaminase differentiate patients with dermatitis herpetiformis from those with linear IgA disease. Journal of the American Academy of Dermatology. 1999;41(6):957-961. Not sensitivity or specificity of an identified test. [pmid: 10570380].
Rosekrans P C, Lindeman J, Meijer C J. Quantitative histological and immunohistochemical findings in jejunal biopsy specimens in giardiasis. Virchows Archiv. A, Pathological Anatomy and Histology. 1981;393(2):145-151. Not sensitivity or specificity of an identified test.
Rosekrans P C, Meijer C J, Polanco I, et al. Long-term morphological and immunohistochemical observations on biopsy specimens of small intestine from children with gluten-sensitive enteropathy. Journal of Clinical Pathology. 1981;34(2):138-144. Unable to extract data. [pmid: 7229092]. [pmcid: 1146439].
Rosenbach Y, Dinari G, Zahavi I, et al. Short stature as the major manifestation of celiac disease in older children. Clin Pediatr. 1986;25(1):13-16. Not sensitivity or specificity of an identified test.
Rosenberg W M, Moss P A, Bell J I. Molecular aspects of autoimmunity: a review. Curr Eye Res 1992;11 Suppl17–23. Not sensitivity or specificity of an identified test
Rosenberg W M, Prince C, Kaklamanis L, et al. Increased expression of CD44v6 and CD44v3 in ulcerative colitis but not colonic Crohn's disease. Lancet. 1995;345(8959):1205-1209. Not sensitivity or specificity of an identified test. [pmid: 7537840].
Rosenberg W M, Wordsworth B P, Jewell D P, et al. A locus telomeric to HLA-DPB encodes susceptibility to coeliac disease. Immunogenetics. 1989;30(4):307-310. Not sensitivity or specificity of an identified test. [pmid: 2571589].
Rosenblatt S, Bassuk J A, Alpers C E, et al. Differential modulation of cell adhesion by interaction between adhesive and counter-adhesive proteins: characterization of the binding of vitronectin to osteonectin (BM40, SPARC). Biochemical Journal. 1997;324(Pt 1):311-319. Not sensitivity or specificity of an identified test. [pmid: 9164872]. [pmcid: 1218432].
Rosenthal D S, Roop D R, Huff C A, et al. Changes in photo-aged human skin following topical application of all-trans retinoic acid. Journal of Investigative Dermatology. 1990;95(5):510-515. Not sensitivity or specificity of an identified test. [pmid: 1700022].
Rosenthal E, Golan D T, Benderly A. Immunofluorescent antigluten antibody test. Titer and profile of gluten antibodies in celiac disease. Am J Dis Child 1984;138(7):659-662. Not sensitivity or specificity of an identified test.
Rossi T M, Tjota A. Serologic indicators of celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1998;26(2):205-210. Not sensitivity or specificity of an identified test. [pmid: 9481639].
Rossi T M, Albini C H, Kumar V. Incidence of celiac disease identified by the presence of serum endomysial antibodies in children with chronic diarrhea, short stature, or insulin-dependent diabetes mellitus. Journal of Pediatrics. 1993;123(2):262-264. Not sensitivity or specificity of an identified test. [pmid: 8345423].
Rossi T M, Kumar V, Lerner A, et al. Relationship of endomysial antibodies to jejunal mucosal pathology: specificity towards both symptomatic and asymptomatic celiacs. Journal of Pediatric Gastroenterology and Nutrition. 1988;7(6):858-863. Serology <1999. [pmid: 3199273].
Rossiter M A, Van Noorden S. Proceedings: Secretin cells in childhood coeliac disease. Archives of Disease in Childhood. 1974;49(3):244. Not sensitivity or specificity of an identified test. [pmid: 4825636].
Rossiter M A, Barrowman J A, Dand A, et al. Amylase content of mixed saliva in children. Acta Paediatr Scand. 1974;63(3):389-392. Not sensitivity or specificity of an identified test. [pmid: 4209508].
Rossiter M A, Palmer T, Evans K, et al. The short term response to a drink of milk, lactose or casein in children with apparently normal gastrointestinal tracts. Br J Nutr. 1974;32(3):605-613. Not sensitivity or specificity of an identified test. [pmid: 4479821].
Rostami K, Mulder C J J. Coeliac disease. A challenging diagnosis. Rom J Gastroenterol. 1999;8(2):111-114. Not sensitivity or specificity of an identified test.
Rostami K, Kerckhaert J P, Tiemessen R, et al. The relationship between anti-endomysium antibodies and villous atrophy in coeliac disease using both monkey and human substrate. European Journal of Gastroenterology & Hepatology. 1999;11(4):439-442. Improper control group. [pmid: 10321762].
Rostami K, Kerckhaert J, Tiemessen R, et al. Sensitivity of antiendomysium and antigliadin antibodies in untreated celiac disease: disappointing in clinical practice. American Journal of Gastroenterology. 1999;94(4):888-894. Improper control group. [pmid: 10201452].
Rostami K, Kerckhaert J, von Blomberg B M, et al. SAT and serology in adult coeliacs, seronegative coeliac disease seems a reality. Netherlands Journal of Medicine. 1998;53(1):15-19. Not sensitivity or specificity of an identified test. [pmid: 9718937].
Rostami K, Mulder C J J, Stapell S, et al. Autoantibodies and histogenesis of celiac disease. Rom J Gastroenterol. 2003;12(2):101-106. Improper control group. [pmid: 12853995].
Rostami K, Mulder C J, van Overbeek F M, et al. Should relatives of coeliacs with mild clinical complaints undergo a small-bowel biopsy despite negative serology?. European Journal of Gastroenterology & Hepatology. 2000;12(1):51-55. Improper control group. [pmid: 10656210].
Rostami K, Mulder C J, Werre J M, et al. High prevalence of celiac disease in apparently healthy blood donors suggests a high prevalence of undiagnosed celiac disease in the Dutch population. Scandinavian Journal of Gastroenterology. 1999;34(3):276-279. Not sensitivity or specificity of an identified test. [pmid: 10232872].
Rostoker G, Delchier J C, Chaumette M T. Increased intestinal intra-epithelial T lymphocytes in primary glomerulonephritis: a role of oral tolerance breakdown in the pathophysiology of human primary glomerulonephritides?. Nephrology, Dialysis, Transplantation - Official Publication of the European Dialysis and Transplant Association - European Renal Association. 2001;16(3):513-517. Not sensitivity or specificity of an identified test. [pmid: 11239024].
Rostoker G, Laurent J, Andre C, et al. High levels of IgA antigliadin antibodies in patients who have IgA mesangial glomerulonephritis but not coeliac disease. Lancet. 1988;1(8581):356-357. Not sensitivity or specificity of an identified test. [pmid: 2893162].
Roth E B, Sjoberg K, Stenberg P. Biochemical and immuno-pathological aspects of tissue transglutaminase in coeliac disease. Autoimmunity. 2003;36(4):221-226. Not sensitivity or specificity of an identified test. [pmid: 14563015].
Rotter J I, Landaw E M. Measuring the genetic contribution of a single locus to a multilocus disease. Clinical Genetics. 1984;26(6):529-542. Not sensitivity or specificity of an identified test. [pmid: 6541983].
Roy-Choudhury D C, Cooke W T, Banwell J G, et al. Multiple jejunal biopsies in adult celiac disease. American Journal of Digestive Diseases. 1967;12(7):657-663. Unable to extract data. [pmid: 6027590].
Roy-Choudhury D, Cooke W T, Tan D T, et al. Jejunal biopsy: criteria and significance. Scandinavian Journal of Gastroenterology. 1966;1(1):57-74. Unable to extract data. [pmid: 4161976].
Ruan E A, Komorowski R A, Hogan W J, et al. Nongranulomatous chronic idiopathic enterocolitis: Clinicopathologic profile and response to corticosteroids. Gastroenterology. 1996;111(3):629-637. Not sensitivity or specificity of an identified test. [pmid: 8780567].
Rubesin S E. Simplified approach to differential diagnosis of small bowel abnormalities. Radiol Clin North Am. 2003;41(2):343-364. Not sensitivity or specificity of an identified test. [pmid: 14661660].
Rubin A L, Rice R H. 2,3,7,8-Tetrachlorodibenzo-p-dioxin and polycyclic aromatic hydrocarbons suppress retinoid-induced tissue transglutaminase in SCC-4 cultured human squamous carcinoma cells. Carcinogenesis. 1988;9(6):1067-1070. Not sensitivity or specificity of an identified test. [pmid: 2897254].
Rubin A L, Parenteau N L, Rice R H. Coordination of keratinocyte programming in human SCC-13 squamous carcinoma and normal epidermal cells. Journal of Cellular Physiology. 1989;138(1):208-214. Not sensitivity or specificity of an identified test. [pmid: 2463259].
Rubin C E, Brandborg L L, Phelps P C et al. Studies of celiac disease. I. The apparent identical and specific nature of the duodenal and proximal jejunal lesion in celiac disease and idiopathic sprue. Gastroenterology 1968;54(4):SupplUnable to extract data
Rubio C A. A simple method to demonstrate duodenal gastric metaplasia. Journal of Clinical Pathology. 2002;55(7):520-523. Not sensitivity or specificity of an identified test. [pmid: 12101215]. [pmcid: 1769704].
Rubio C A, Theorell M, Befrits R, et al. The characteristics of mitotic figures in jejunal mucosa of patients with celiac disease. Am J Clin Pathol. 1992;98(6):575-578. Not sensitivity or specificity of an identified test. [pmid: 1462955].
Rudchenko S, Trakht I, Sobel J H. Comparative structural and functional features of the human fibrinogen alpha C domain and the isolated alpha C fragment. Characterization using monoclonal antibodies to defined COOH-terminal A alpha chain regions. Journal of Biological Chemistry. 1996;271(5):2523-2530. Not sensitivity or specificity of an identified test. [pmid: 8576216].
Rude R K, Olerich M. Magnesium deficiency: Possible role in osteoporosis associated with gluten-sensitive enteropathy. Osteoporosis Int. 1996;6(6):453-461. Not sensitivity or specificity of an identified test.
Rudolph P, Schubert C, Zelger B G, et al. Differential expression of CD34 and Ki-M1p in pleomorphic fibroma and dermatofibroma with monster cells. American Journal of Dermatopathology. 1999;21(5):414-419. Not sensitivity or specificity of an identified test. [pmid: 10535568].
Rudy G, Lew A M. Limited polymorphism of the HLA-DQA2 promoter and identification of a variant octamer. Human Immunology. 1994;39(3):225-229. Not sensitivity or specificity of an identified test. [pmid: 8026991].
Rueda B, Pascual M, Lopez-Nevot M A, et al. A new allele within the transmembrane region of the human MICA gene with seven GCT repeats. Tissue Antigens. 2002;60(6):526-528. Not sensitivity or specificity of an identified test. [pmid: 12542746].
Rueda B, Pascual M, Lopez-Nevot M A, et al. Association of MICA-A5.1 allele with susceptibility to celiac disease in a family study. American Journal of Gastroenterology. 2003;98(2):359-362. Not sensitivity or specificity of an identified test. [pmid: 12591055].
Rueda Blanca, Lopez-Nevot Miguel, Angel Pascual, et al. Polymorphism of the inducible nitric oxide synthase gene in celiac disease. Human Immunology. 2002;63(11):1062-1065. Not sensitivity or specificity of an identified test. [pmid: 12392860].
Ruiz del, Prado M Y, Olivares Lopez J L, et al. HLA system. Phenotypic and gene frequencies in celiac and healthy subjects from the same geographical area. Revista Espanola De Enfermedades Digestivas - Organo Oficial De La Sociedad Espanola De Patologia Digestiva. 2001;93(2):106-113. Improper control group. [pmid: 11471223].
Ruiz M Y, Olivares J L. Three-loci HLA haplotypes in Spanish celiac children and healthy subjects: estimation of linkage disequilibrium and haplotype frequencies. American Journal of Gastroenterology. 2001;96(5):1455-1459. Improper control group. [pmid: 11374682].
Rujner J, Socha J, Barra E, et al. Serum and salivary antigliadin antibodies and serum IgA anti-endomysium antibodies as a screening test for coeliac disease. Acta Paediatrica (Oslo, Norway - 1992). 1996;85(7):814-817. Improper control group. [pmid: 8819547].
Rujner J, Wisniewski A, Gregorek H, et al. Coeliac disease and HLA-DQ 2 (DQA1* 0501 and DQB1* 0201) in patients with Turner syndrome. Journal of Pediatric Gastroenterology and Nutrition. 2001;32(1):114-115. Not sensitivity or specificity of an identified test. [pmid: 11176342].
Rumbo M, Chirdo F G, Anon M C, et al. Detection and characterization of antibodies specific to food antigens (gliadin, ovalbumin and beta-lactoglobulin) in human serum, saliva, colostrum and milk. Clinical and Experimental Immunology. 1998;112(3):453-458. Not sensitivity or specificity of an identified test. [pmid: 9649214]. [pmcid: 1904991].
Rumbo M, Chirdo F G, Ben R, et al. Evaluation of coeliac disease serological markers in Down syndrome patients. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(2):116-121. Not sensitivity or specificity of an identified test. [pmid: 11926554].
Runmarker B, Martinsson T, Wahlstrom J, et al. HLA and prognosis in multiple sclerosis. J Neurol. 1994;241(6):385-390. Not sensitivity or specificity of an identified test. [pmid: 7931434].
Russell R I, Atherton S T, Nelson L M. Effect of an elemental diet (Vivonex) on the absorption abnormalities and histological appearances of the jejunum in untreated adult coeliac disease. Digestion. 1979;19(5):335-339. Not sensitivity or specificity of an identified test. [pmid: 488554].
Rust C, Kooy Y, Pena S, et al. Phenotypical and functional characterization of small intestinal TcR gamma delta + T cells in coeliac disease. Scandinavian Journal of Immunology. 1992;35(4):459-468. Not sensitivity or specificity of an identified test. [pmid: 1532668].
Rustgi A K, Peppercorn M A. Gluten-sensitive enteropathy and systemic lupus erythematosus. Archives of Internal Medicine. 1988;148(7):1583-1584. Not sensitivity or specificity of an identified test. [pmid: 3260095].
Rutgeerts L, Tytgat G, Mainguet P, et al. Enterokinase activity of normal and flat duodenal mucosa. Acta Gastro-Enterol Belg. 1973;36(9):449-455. Not sensitivity or specificity of an identified test.
Rutz Regula, Ritzler Eva, Fierz Walter, et al. Prevalence of asymptomatic celiac disease in adolescents of eastern Switzerland. Swiss Medical Weekly - Official Journal of the Swiss Society of Infectious Diseases, the Swiss Society of Internal Medicine, the Swiss Society of Pneumology. 2002;132(34):43-47. Not sensitivity or specificity of an identified test. [pmid: 11953905].
Ryan B M, Kelleher D. Refractory celiac disease. Gastroenterology. 2000;119(1):243-251. Not sensitivity or specificity of an identified test. [pmid: 10889175].
Rybakowski J K, Chorzelski T P, Sulej J. Lack of Ig A-class endomysial antibodies, the specific marker of gluten enteropathy, in sera of schizophrenic patients. Med Sci Res. 1990;18(8):311. Not sensitivity or specificity of an identified test.
Saalman R, Dahlgren U I, Fallstrom S P, et al. Avidity progression of dietary antibodies in healthy and coeliac children. Clinical and Experimental Immunology. 2003;134(2):328-334. Not sensitivity or specificity of an identified test. [pmid: 14616795]. [pmcid: 1808872].
Saalman R, Dahlgren U I, Fallstrom S P, et al. IgG subclass profile of serum antigliadin antibodies and antibody-dependent cell-mediated cytotoxicity in young children with coeliac disease. Scandinavian Journal of Immunology. 2001;53(1):92-98. Not sensitivity or specificity of an identified test. [pmid: 11169212].
Saalman R, Wold A E, Dahlgren U I, et al. Antibody-dependent cell-mediated cytotoxicity to gliadin-coated cells with sera from children with coeliac disease. Scandinavian Journal of Immunology. 1998;47(1):37-42. Not sensitivity or specificity of an identified test. [pmid: 9467656].
Saari K M. HLA and coeliac disease. Acta Ophthalmol. 1984;62(Suppl 165):107-109. Not sensitivity or specificity of an identified test.
Sacchetti L, Ferrajolo A, Salerno G, et al. Diagnostic value of various serum antibodies detected by diverse methods in childhood celiac disease. Clinical Chemistry. 1996;42(11):1838-1842. Improper control group. [pmid: 8906085].
Sacchetti L, Sarrantonio C, Pastore L, et al. Rapid identification of HLA DQA1*0501, DQB1*0201 and DRB1*04 alleles in celiac disease by a PCR-based methodology. Clinical Chemistry. 1997;43(11):2204-2206. Not sensitivity or specificity of an identified test. [pmid: 9365418].
Sacchetti L, Tinto N, Calcagno G et al. Multiplex PCR typing of the three most frequent HLA alleles in celiac disease. Clinica Chimica Acta 2001;International Journal of Clinical Chemistry; 310(2):205–207. Not sensitivity or specificity of an identified test
Sachdev A, Srinivasan V, Maheswary S, et al. Adult onset celiac disease in north India. Tropical Gastroenterology - Official Journal of the Digestive Diseases Foundation. 2002;23(3):117-119. Not sensitivity or specificity of an identified test. [pmid: 12693151].
Sachs J A, Awad J, McCloskey D, et al. Different HLA associated gene combinations contribute to susceptibility for coeliac disease and dermatitis herpetiformis. Gut. 1986;27(5):515-520. Not sensitivity or specificity of an identified test. [pmid: 3457750]. [pmcid: 1433500].
Sacks S H, Bushell A, Rust N A, et al. Functional and biochemical subtypes of the haplotype HLA-DR3 in patients with celiac disease or idiopathic membranous nephropathy. Hum Immunol. 1987;20(2):175-187. Not sensitivity or specificity of an identified test. [pmid: 2960642].
Sadikali F, Darwish R, Watson W C. Carnosinase activity of human gastrointestinal mucosa. Gut. 1975;16(8):585-589. Not sensitivity or specificity of an identified test. [pmid: 1237444]. [pmcid: 1411017].
Safwenberg J, Kollberg H, Lindblom J B. HLA frequencies in patients with cystic fibrosis. Tissue Antigens. 1977;10(4):287-290. Not sensitivity or specificity of an identified test. [pmid: 918940].
Saga K. Histochemical and immunohistochemical markers for human eccrine and apocrine sweat glands: an aid for histopathologic differentiation of sweat gland tumors. Journal of Investigative Dermatology.Symposium Proceedings / the Society for Investigative Dermatology, Inc.And European Society for Dermatological Research 2001;6(1):49–53. Not sensitivity or specificity of an identified test
Sagaro E, Jimenez N. Family studies of coeliac disease in Cuba. Archives of Disease in Childhood. 1981;56(2):132-133. Not sensitivity or specificity of an identified test. [pmid: 7469464].
Saito S, Ota S, Hashizume K, et al. A new HLA-DQB1(*)0306 allele sharing motifs from DQB1(*)03032 and DQB1(*)04 sequences. Tissue Antigens. 1996;48(5):580-585. Not sensitivity or specificity of an identified test. [pmid: 8988541].
Sakai K, Busby W H, Clarke J B, et al. Tissue transglutaminase facilitates the polymerization of insulin-like growth factor-binding protein-1 (IGFBP-1) and leads to loss of IGFBP-1's ability to inhibit insulin-like growth factor-I-stimulated protein synthesis. Journal of Biological Chemistry. 2001;276(12):8740-8745. Not sensitivity or specificity of an identified test. [pmid: 11121406].
Salazar de, Sousa Magalhaes, Ramalho P, et al. Reaction of rectal mucosa of celiac patients to direct contact with gluten. Journal of Pediatric Gastroenterology and Nutrition. 1988;7(3):403-405. Not sensitivity or specificity of an identified test. [pmid: 3385553].
Salerno Giuseppe, De Franco, Antonio La, et al. Malabsorption syndromes. Rays. 2002;27(1):19-34. Not sensitivity or specificity of an identified test. [pmid: 12696272].
Salmela M T, Karjalainen-Lindsberg M L, Jeskanen L, et al. Overexpression of tissue inhibitor of metalloproteinases-3 in intestinal and cutaneous lesions of graft-versus-host disease. Mod Pathol. 2003;16(2):108-114. Not sensitivity or specificity of an identified test. [pmid: 12591962].
Salmela M T, Pender S L, Reunala T, et al. Parallel expression of macrophage metalloelastase (MMP-12) in duodenal and skin lesions of patients with dermatitis herpetiformis. Gut. 2001;48(4):496-502. Not sensitivity or specificity of an identified test. [pmid: 11247893]. [pmcid: 1728241].
Salur L, Uibo O, Talvik I, et al. The high frequency of coeliac disease among children with neurological disorders. European Journal of Neurology - the Official Journal of the European Federation of Neurological Societies. 2000;7(6):707-711. Not sensitivity or specificity of an identified test. [pmid: 11136360].
Salvati V M, Bajaj-Elliott M, Poulsom R, et al. Keratinocyte growth factor and coeliac disease. Gut. 2001;49(2):176-181. Not sensitivity or specificity of an identified test. [pmid: 11454791]. [pmcid: 1728384].
Salvati V M, MacDonald T T, Blanco G D V, et al. Enhanced expression of interferon regulatory factor-1 in the mucosa of children with celiac disease. Pediatric Research. 2003;54(3):312-318. Not sensitivity or specificity of an identified test. [pmid: 12788988].
Sanchez D, Tuckova L, Sebo P, et al. Occurrence of IgA and IgG autoantibodies to calreticulin in coeliac disease and various autoimmune diseases. Journal of Autoimmunity. 2000;15(4):441-449. Not sensitivity or specificity of an identified test. [pmid: 11090243].
Sanchez-Albisua I, Storm W, Wascher I, et al. How frequent is coeliac disease in Down syndrome?. European Journal of Pediatrics. 2002;161(12):683-684. Not sensitivity or specificity of an identified test. [pmid: 12536992].
Sanders D S, Carter M J, Hurlstone D P, et al. Association of adult coeliac disease with irritable bowel syndrome: a case-control study in patients fulfilling ROME II criteria referred to secondary care. Lancet. 2001;358(9292):1504-1508. Not sensitivity or specificity of an identified test. [pmid: 11705563].
Sanders D S, Perry I, Hardy R, et al. Aberrant P-cadherin expression is a feature of clonal expansion in the gastrointestinal tract associated with repair and neoplasia. Journal of Pathology. 2000;190(5):526-530. Not sensitivity or specificity of an identified test. [pmid: 10727977].
Sanders David S, Patel Dina, Stephenson Timothy J, et al. A primary care cross-sectional study of undiagnosed adult coeliac disease. European Journal of Gastroenterology & Hepatology. 2003;15(4):407-413. Not sensitivity or specificity of an identified test. [pmid: 12655262].
Sanderson J, Marcantonio J M, Duncan G. A human lens model of cortical cataract: Casup 2sup +-induced protein loss, vimentin cleavage and opacification. Invest Ophthalmol Vis Sci. 2000;41(8):2255-2261. Not sensitivity or specificity of an identified test. [pmid: 10892870].
Sanderson M C, Davis L R, Mowat A P. Failure of laboratory and radiological studies to predict jejunal mucosal atrophy. Archives of Disease in Childhood. 1975;50(7):526-531. Not sensitivity or specificity of an identified test. [pmid: 170871].
Sanfilippo G, Patane R, Fusto A, et al. Endoscopic approach to childhood coeliac disease. Acta Gastro-Enterologica Belgica. 1986;49(4):401-408. Unable to extract data. [pmid: 3577609].
Sanjeevi C B. HLA-DQ6-mediated protection in IDDM. Human Immunology. 2000;61(2):148-153. Not sensitivity or specificity of an identified test. [pmid: 10717807].
Sanjeevi C B, DeWeese C, Landin-Olsson M, et al. Analysis of critical residues of HLA-DQ6 molecules in insulin-dependent diabetes mellitus. Tissue Antigens. 1997;50(1):61-65. Not sensitivity or specificity of an identified test. [pmid: 9243758].
Sanjeevi C B, Falorni A, Kockum I, et al. HLA and glutamic acid decarboxylase in human insulin-dependent diabetes mellitus. Diabetic Med. 1996;13(3):209-217. Not sensitivity or specificity of an identified test. [pmid: 8689840].
Sanjeevi C B, Hagopian W A, Landin-Olsson M, et al. Association between autoantibody markers and subtypes of DR4 and DR4-DQ in Swedish children with insulin-dependent diabetes reveals closer association of tyrosine pyrophosphatase autoimmunity with DR4 than DQ8. Tissue Antigens. 1998;51(3):281-286. Not sensitivity or specificity of an identified test. [pmid: 9550329].
Sanjeevi C B, Hook P, Landin-Olsson M, et al. DR4 subtypes and their molecular properties in a population-based study of Swedish childhood diabetes. Tissue Antigens. 1996;47(4):275-283. Not sensitivity or specificity of an identified test. [pmid: 8773316].
Sanjeevi C B, Kanungo A, Samal K C. Immunogenetic studies on malnutrition-modulated diabetes mellitus. Annals of the New York Academy of Sciences 2002;958144–147. Not sensitivity or specificity of an identified test
Sanjeevi C B, Kanungo A, Shtauvere A, et al. Association of HLA class II alleles with different subgroups of diabetes mellitus in Eastern India identify different associations with IDDM and malnutrition-related diabetes. Tissue Antigens. 1999;54(1):83-87. Not sensitivity or specificity of an identified test. [pmid: 10458326].
Sanjeevi C B, Landin-Olsson M, Kockum I et al. The combination of several polymorphic amino acid residues in the DQalpha and DQbeta chains forms a domain structure pattern and is associated with insulin-dependent diabetes mellitus. Annals of the New York Academy of Sciences 2002;958362–375. Not sensitivity or specificity of an identified test
Sanjeevi C B, Landin-Olsson M, Kockum I, et al. Effects of the second HLA-DQ haplotype on the association with childhood insulin-dependent diabetes mellitus. Tissue Antigens. 1995;45(2):148-152. Not sensitivity or specificity of an identified test. [pmid: 7792764].
Sanjeevi C B, Lybrand T P, DeWeese C, et al. Polymorphic amino acid variations in HLA-DQ are associated with systematic physical property changes and occurrence of IDDM. Diabetes. 1995;44(1):125-131. Not sensitivity or specificity of an identified test. [pmid: 7813806].
Sanjeevi C B, Lybrand T P, Landin-Olsson M, et al. Analysis of antibody markers, DRB1, DRB5, DQA1 and DQB1 genes and modeling of DR2 molecules in DR2-positive patients with insulin-dependent diabetes mellitus. Tissue Antigens. 1994;44(2):110-119. Not sensitivity or specificity of an identified test. [pmid: 7817375].
Sanjeevi C B, Lybrand T P, Stevanovic S et al. Molecular modeling of eluted peptides from DQ6 molecules (DQB1*0602 and DQB1*0604) negatively and positively associated with type 1 diabetes. Annals of the New York Academy of Sciences 2002;958317–320. Not sensitivity or specificity of an identified test
Santos S, Balas A, Lillo R, et al. HLA-B14 subtyping by semi-nested PCR-SSP and haplotype distribution in a Spanish population. Tissue Antigens. 1997;50(6):671-674. Not sensitivity or specificity of an identified test. [pmid: 9458126].
Sapp Heidi, Ithamukkala Sarathehandra, Brien Tom P, et al. The terminal ileum is affected in patients with lymphocytic or collagenous colitis. American Journal of Surgical Pathology. 2002;26(11):1484-1492. Not sensitivity or specificity of an identified test. [pmid: 12409725].
Saputo V, Losi S, Mancosu M, et al. Intraepithelial lymphocytes in jejunal mucosa: diagnostic significance of changes in their number during chronic intestinal disease, with particular reference to coeliac disease. Schweizerische Rundschau Fur Medizin Praxis = Revue Suisse De Medecine Praxis. 1981;70(30):1342-1348. Unable to extract data. [pmid: 7267614].
Sardy M, Karpati S, Peterfy F, et al. Comparison of a tissue transglutaminase ELISA with the endomysium antibody test in the diagnosis of gluten-sensitive enteropathy. Zeitschrift Fur Gastroenterologie. 2000;38(5):357-364. Improper control group. [pmid: 10875144].
Sardy M, Odenthal U, Karpati S, et al. Recombinant human tissue transglutaminase ELISA for the diagnosis of gluten-sensitive enteropathy. Clinical Chemistry. 1999;45(12):2142-2149. Improper control group. [pmid: 10585346].
Sardy Miklos, Karpati Sarolta, Merkl Barbara, et al. Epidermal transglutaminase (TGase 3) is the autoantigen of dermatitis herpetiformis. Journal of Experimental Medicine. 2002;195(6):747-757. Not sensitivity or specificity of an identified test. [pmid: 11901200].
Sarles J, Gorvel J P, Olive D, et al. Subcellular localization of class I (A,B,C) and class II (DR and DQ) MHC antigens in jejunal epithelium of children with coeliac disease. Journal of Pediatric Gastroenterology and Nutrition. 1987;6(1):51-56. Not sensitivity or specificity of an identified test. [pmid: 3540260].
Sarsfield P, Jones D B, Wright D H. Accessory cells in Crohn's disease of the terminal ileum. Histopathology. 1996;28(3):213-219. Not sensitivity or specificity of an identified test. [pmid: 8729039].
Sarsfield P, Rinne A, Jones D B, et al. Accessory cells in physiological lymphoid tissue from the intestine: an immunohistochemical study. Histopathology. 1996;28(3):205-211. Not sensitivity or specificity of an identified test. [pmid: 8729038].
Sasado T, Kani S, Washimi K, et al. Expression of murine early embryonic antigens, SSEA-1 and antigenic determinant of EMA-1, in embryos and ovarian follicles of a teleost medaka (Oryzias latipes). Dev Growth Differ. 1999;41(3):293-302. Not sensitivity or specificity of an identified test. [pmid: 10400391].
Sategna Guidetti, Carla Scaglione, Nadia Martini, et al. Red cell distribution width as a marker of coeliac disease: a prospective study. European Journal of Gastroenterology & Hepatology. 2002;14(2):177-181. Not sensitivity or specificity of an identified test. [pmid: 11981342].
Sategna-Guidetti C, Grosso S. Changing pattern in adult coeliac disease: A 24-year survey. European Journal of Gastroenterology & Hepatology. 1994;6(1):15-19. Not sensitivity or specificity of an identified test.
Sategna-Guidetti C, Bruno M, Mazza E, et al. Autoimmune thyroid diseases and coeliac disease. European Journal of Gastroenterology & Hepatology. 1998;10(11):927-931. Not sensitivity or specificity of an identified test. [pmid: 9872614].
Sategna-Guidetti C, Bruno M, Pulitano R, et al. Disease specificity of IgA class anti-endomysium antibodies (IgA-EmA) in adult coeliac disease. European Journal of Gastroenterology & Hepatology. 1991;3(3):251-254. Not sensitivity or specificity of an identified test.
Sategna-Guidetti C, Ferfoglia G, Bruno M, et al. Do IgA antigliadin and IgA antiendomysium antibodies show there is latent coeliac disease in primary IgA nephropathy?. Gut. 1992;33(4):476-478. Not sensitivity or specificity of an identified test. [pmid: 1582590]. [pmcid: 1374062].
Sategna-Guidetti C, Grosso S B, Bruno M, et al. Indirect immunofluorescence for of anti-jejunum antibody detection in celiac disease: comparison among different antigenic substrates. Panminerva Medica. 1998;40(4):261-263. Not sensitivity or specificity of an identified test. [pmid: 9973817].
Sategna-Guidetti C, Grosso S B, Bruno M, et al. Is human umbilical cord the most suitable substrate for the detection of endomysium antibodies in the screening and follow-up of coeliac disease?. European Journal of Gastroenterology & Hepatology. 1997;9(7):657-660. Improper control group. [pmid: 9262972].
Sategna-Guidetti C, Grosso S B, Grosso S, et al. The effects of 1-year gluten withdrawal on bone mass, bone metabolism and nutritional status in newly-diagnosed adult coeliac disease patients. Alimentary Pharmacology & Therapeutics. 2000;14(1):35-43. Not sensitivity or specificity of an identified test. [pmid: 10632643].
Sategna-Guidetti C, Grosso S, Bruno M, et al. Reliability of immunologic markers of celiac sprue in the assessment of mucosal recovery after gluten withdrawal. Journal of Clinical Gastroenterology. 1996;23(2):101-104. Not sensitivity or specificity of an identified test. [pmid: 8877634].
Sategna-Guidetti C, Grosso S, Pulitano R, et al. Celiac disease and insulin-dependent diabetes mellitus. Screening in an adult population. Digestive Diseases and Sciences. 1994;39(8):1633-1637. Not sensitivity or specificity of an identified test. [pmid: 8050311].
Sategna-Guidetti C, Pulitano R, Grosso S, et al. Serum IgA antiendomysium antibody titers as a marker of intestinal involvement and diet compliance in adult celiac sprue. Journal of Clinical Gastroenterology. 1993;17(2):123-127. Not sensitivity or specificity of an identified test. [pmid: 8409314].
Sategna-Guidetti C, Volta U, Ciacci C, et al. Prevalence of thyroid disorders in untreated adult celiac disease patients and effect of gluten withdrawal: an Italian multicenter study. American Journal of Gastroenterology. 2001;96(3):751-757. Not sensitivity or specificity of an identified test. [pmid: 11280546].
Satsangi J, Welsh K I, Bunce M, et al. Contribution of genes of the major histocompatibility complex to susceptibility and disease phenotype in inflammatory bowel disease. Lancet. 1996;347(9010):1212-1217. Not sensitivity or specificity of an identified test. [pmid: 8622450].
Saukkonen T, Ilonen J, Akerblom H K, et al. Prevalence of coeliac disease in siblings of patients with Type I diabetes is related to the prevalence of DQB1*02 allele. Diabetologia. 2001;44(8):1051-1053. Improper control group. [pmid: 11484084].
Saukkonen T, Savilahti E, Reijonen H, et al. Coeliac disease: frequent occurrence after clinical onset of insulin-dependent diabetes mellitus. Childhood Diabetes in Finland Study Group. Diabetic Medicine - a Journal of the British Diabetic Association. 1996;13(5):464-470. Not sensitivity or specificity of an identified test. [pmid: 8737029].
Savage D A, Middleton D, Trainor F, et al. HLA class II frequencies in celiac disease patients in the west of Ireland. Human Immunology. 1992;34(1):47-52. Not sensitivity or specificity of an identified test. [pmid: 1356956].
Saverymuttu S H, Sabbat J, Burke M, et al. Impact of endoscopic duodenal biopsy on the detection of small intestinal villous atrophy. Postgraduate Medical Journal. 1991;67(783):47-49. Unable to extract data. [pmid: 2057427].
Savidge T C, Shmakov A N, Walker-Smith J A, et al. Epithelial cell proliferation in childhood enteropathies. Gut. 1996;39(2):185-193. Not sensitivity or specificity of an identified test. [pmid: 8977336]. [pmcid: 1383296].
Savilahti E. IgA deficiency in children. Immunoglobulin-containing cells in the intestinal mucosa, immunoglobulins in secretions and serum IgA levels. Clinical and Experimental Immunology. 1973;13(3):395-406. Not sensitivity or specificity of an identified test. [pmid: 4633850]. [pmcid: 1553771].
Savilahti E, Arato A, Verkasalo M. Intestinal gamma/delta receptor-bearing T lymphocytes in celiac disease and inflammatory bowel diseases in children. Constant increase in celiac disease. Pediatric Research 1990;28(6):579-581. Not sensitivity or specificity of an identified test.
Savilahti E, Launiala K, Kuitunen P. Jejunal disaccharidases in children with selective IgA deficiency. Scandinavian Journal of Gastroenterology. 1973;8(5):417-419. Not sensitivity or specificity of an identified test. [pmid: 4201738].
Savilahti E, Ormala T, Arato A, et al. Density of gamma/deltasup + T cells in the jejunal epithelium of patients with coeliac disease and dermatitis herpetiformis is increased with age. Clinical and Experimental Immunology. 1997;109(3):464-467. Not sensitivity or specificity of an identified test. [pmid: 9328123]. [pmcid: 1904772].
Savilahti E, Ormala T, Saukkonen T, et al. Jejuna of patients with insulin-dependent diabetes mellitus (IDDM) show signs of immune activation. Clinical and Experimental Immunology. 1999;116(1):70-77. Not sensitivity or specificity of an identified test. [pmid: 10209507]. [pmcid: 1905225].
Savilahti E, Pelkonen P, Verkasalo M, et al. Selective deficiency of immunoglobulin A in children. Klinische Padiatrie. 1985;197(4):336-340. Not sensitivity or specificity of an identified test. [pmid: 4046491].
Savilahti E, Reunala T, Maki M. Increase of lymphocytes bearing the gamma/delta T cell receptor in the jejunum of patients with dermatitis herpetiformis. Gut. 1992;33(2):206-211. Not sensitivity or specificity of an identified test. [pmid: 1531801]. [pmcid: 1373931].
Savilahti E, Simell O, Koskimies S, et al. Celiac disease in insulin-dependent diabetes mellitus. Journal of Pediatrics. 1986;108(5 Pt 1):690-693. Improper control group. [pmid: 3701514].
Savilahti E, Viander M, Perkkio M, et al. IgA antigliadin antibodies: a marker of mucosal damage in childhood coeliac disease. Lancet. 1983;1(8320):320-322. Not sensitivity or specificity of an identified test. [pmid: 6130332].
Sblattero D, Florian F, Not T, et al. Analyzing the peripheral blood antibody repertoire of a celiac disease patient using phage antibody libraries. Human Antibodies. 2000;9(4):199-205. Not sensitivity or specificity of an identified test. [pmid: 11341173].
Sblattero Daniele, Florian Fiorella, Azzoni Elisabetta, et al. The analysis of the fine specificity of celiac disease antibodies using tissue transglutaminase fragments. European Journal of Biochemistry / Febs. 2002;269(21):5175-5181. Not sensitivity or specificity of an identified test. [pmid: 12392549].
Scalici C, Manzoni D, Licastro G, et al. Reliability of EMA assay in the evaluation of gluten-free diet compliance in celiac patients during follow-up. Acta Med Mediterr. 2003;19(1):67-69. Not sensitivity or specificity of an identified test.
Schaad U, Gaze H, Hadorn B. Value of 1-hour blood-xylose test in diagnosis of childhood coeliac disease. Arch Dis Child. 1978;53(5):420-422. Not sensitivity or specificity of an identified test. [pmid: 718246].
Schaffer M, Olerup O. A novel DRB1(*)13 allele (DRB1(*)1327) on a DR17,DQ2 haplotype with a DRB1(*)0301 sequence motif in the 2nd hyperpolymorphic region. Tissue Antigens. 1997;49(2):186-188. Not sensitivity or specificity of an identified test. [pmid: 9062978].
Schattner A, Kozak N, Lassry Y, et al. Primary intestinal T-cell lymphoma and sclerosing cholangitis: A cytokine-mediated association?. J Intern Med (Gbr). 1998;244(6):537-541. Not sensitivity or specificity of an identified test.
Schaumburg-Lever G, Gehring B, Kaiserling E. Ultrastructural localization of factor XIIIa. Journal of Cutaneous Pathology. 1994;21(2):129-134. Not sensitivity or specificity of an identified test. [pmid: 7913718].
Schenk E A, Samloff I M. Clinical and morphologic changes following gluten administration to patients with treated celiac dsease. American Journal of Pathology. 1968;52(3):579-593. Unable to extract data. [pmid: 5642926]. [pmcid: 2013423].
Schenk E A, Samloff I M, Klipstein F A. Morphologic characteristics of jejunal biopsy in celiac disease and tropical sprue. American Journal of Pathology. 1965;47(5):765-781. Not sensitivity or specificity of an identified test. [pmid: 5843417].
Schenk E A, Samloff I M, Klipstein F A. Morphology of small bowel biopsies. American Journal of Clinical Nutrition. 1968;21(9):944-961. Not sensitivity or specificity of an identified test. [pmid: 5675858].
Schenker S. Adverse reactions to food. Nutr Bull. 2002;27(2):125-127. Not sensitivity or specificity of an identified test.
Scherak O, Smolen J S, Mayr W R. HLA-DRw3 and systemic lupus erythematosus. Arthritis Rheum. 1980;23(8):954-957. Not sensitivity or specificity of an identified test. [pmid: 6967729].
Schmid D G, der Mulbe F D, Fleckenstein B, et al. Broadband detection electrospray ionization Fourier transform ion cyclotron resonance mass spectrometry to reveal enzymatically and chemically induced deamidation reactions within peptides. Analytical Chemistry. 2001;73(24):6008-6013. Not sensitivity or specificity of an identified test. [pmid: 11791573].
Schmidt R, Michel S, Shroot B, et al. Transglutaminases in normal and transformed human keratinocytes in culture. Journal of Investigative Dermatology. 1988;90(4):475-479. Not sensitivity or specificity of an identified test. [pmid: 2450930].
Schmitz J. Is celiac disease a lifelong disorder?. Clinical and Investigative Medicine. Medecine Clinique Et Experimentale. 1996;19(5):352-356. Not sensitivity or specificity of an identified test. [pmid: 8889273].
Schmitz J. Lack of oats toxicity in coeliac disease. Br Med J. 1997;314(7075):159-160. Not sensitivity or specificity of an identified test. [pmid: 9022420]. [pmcid: 2125662].
Schneppenheim R, Budde U, Dahlmann N, et al. Luminography--a new, highly sensitive visualization method for electrophoresis. Electrophoresis. 1991;12(5):367-372. Not sensitivity or specificity of an identified test. [pmid: 1682145].
Schober E, Bittmann B, Granditsch G, et al. Screening by anti-endomysium antibody for celiac disease in diabetic children and adolescents in Austria. Journal of Pediatric Gastroenterology and Nutrition. 2000;30(4):391-396. Not sensitivity or specificity of an identified test. [pmid: 10776949].
Schober Edith, Rami Birgit, Granditsch Gerhard, et al. Coeliac disease in children and adolescents with type 1 diabetes mellitus: to screen or not, to treat or not?. Hormone Research. 2002;57(Suppl 1):97-100. Not sensitivity or specificity of an identified test. [pmid: 11979035].
Scholz S, Albert E. HLA and diseases: involvement of more than one HLA-linked determinant of disease susceptibility. Immunological Reviews 1983;7077–88. Not sensitivity or specificity of an identified test
Schroeder W T, Thacher S M, Stewart-Galetka S, et al. Type I keratinocyte transglutaminase: expression in human skin and psoriasis. Journal of Investigative Dermatology. 1992;99(1):27-34. Not sensitivity or specificity of an identified test. [pmid: 1351505].
Schulzke J D, Bentzel C J, Schulzke I, et al. Epithelial tight junction structure in the jejunum of children with acute and treated celiac sprue. Pediatric Research. 1998;43(4 Pt 1):435-441. Not sensitivity or specificity of an identified test. [pmid: 9544995].
Schulzke J D, Schulzke I, Fromm M, et al. Epithelial barrier and ion transport in coeliac sprue: electrical measurements on intestinal aspiration biopsy specimens. Gut. 1995;37(6):777-782. Not sensitivity or specificity of an identified test. [pmid: 8537047]. [pmcid: 1382938].
Schuppan D, Ciccocioppo R. Coeliac disease and secondary autoimmunity. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(1):13-15. Not sensitivity or specificity of an identified test. [pmid: 11926568].
Schuppan D, Hahn E G. Celiac disease and its link to type 1 diabetes mellitus. Journal of Pediatric Endocrinology & Metabolism 2001;14 Suppl 1597–605. Not sensitivity or specificity of an identified test
Schuppan D, Hahn E G. IgA anti-tissue transglutaminase: setting the stage for coeliac disease screening. European Journal of Gastroenterology & Hepatology. 2001;13(6):635-637. Not sensitivity or specificity of an identified test. [pmid: 11434587].
Schuppan D, Dieterich W, Riecken E O. Exposing gliadin as a tasty food for lymphocytes. Nature Medicine. 1998;4(6):666-667. Not sensitivity or specificity of an identified test. [pmid: 9623970].
Schuppan D, Dieterich W, Ehnis T et al. Identification of the autoantigen of celiac disease. Annals of the New York Academy of Sciences 1998;859121–126. Not sensitivity or specificity of an identified test
Schuppan D, Ruehl M, Somasundaram R, et al. Matrix as a modulator of hepatic fibrogenesis. Seminars in Liver Disease. 2001;21(3):351-372. Not sensitivity or specificity of an identified test. [pmid: 11586465].
Schuppan Detlef, Hahn Eckhart G. Biomedicine. Gluten and the gut-lessons for immune regulation. Science. 2002;297(5590):2218-2220. Not sensitivity or specificity of an identified test. [pmid: 12351776].
Schuppan Detlef, Esslinger Birgit, Dieterich Walburga. Innate immunity and coeliac disease. Lancet. 2003;362(9377):3-4. Not sensitivity or specificity of an identified test. [pmid: 12853196].
Schutz S M, Stroebel J, Schutz E M, et al. Celiac sprue. Diagnosis and diet: keys to recovery. North Carolina Medical Journal. 1994;55(1):32-36. Not sensitivity or specificity of an identified test. [pmid: 8121500].
Schwartz F C M, Lunat M, Wolfsdorf J. Blood xylose concentrations in protein energy malnutrition. Relationship to serum albumin and jejunal histology. S Afr Med J 1974;48(58):2387-2390. Not sensitivity or specificity of an identified test.
Schweiger G D, Murray J A. Postbulbar duodenal ulceration and stenosis associated with celiac disease. Abdom Imaging. 1998;23(4):347-349. Not sensitivity or specificity of an identified test. [pmid: 9663266].
Schweizer J J, Mearin M L, Pena A S, et al. Expression of HLA-DQ antigens in the small-intestinal mucosa of patients with coeliac disease. Scandinavian Journal of Gastroenterology. 1991;26(6):605-610. Not sensitivity or specificity of an identified test. [pmid: 1862299].
Scoglio Riccardo, Di Pasquale, Giuseppe Pagano, et al. Is intestinal biopsy always needed for diagnosis of celiac disease?. American Journal of Gastroenterology. 2003;98(6):1325-1331. Improper control group. [pmid: 12818277].
Scott Losowsky B B M S. Coeliac disease with mild mucosal abnormalities: a report of our patients. Postgrad Med J. 1977;53(617):134-138. Improper control group. [pmid: 870890].
Scott B B, Losowsky M S. Patchiness and duodenal-jejunal variation of the mucosal abnormality in coeliac disease and dermatitis herpetiformis. Gut. 1976;17(12):984-992. Unable to extract data. [pmid: 1017719]. [pmcid: 1411232].
Scott B B, Losowsky M S. Proceedings: Patchiness of the mucosal abnormality in coeliac disease (CD) and dermatitis herpetiformis (DH). Gut. 1975;16(5):393. Unable to extract data. [pmid: 273].
Scott B B, Fairman M J, Toothill C, et al. The expression enzyme activity of biopsy tissue from the small intestine. Digestion. 1977;15(3):182-187. Not sensitivity or specificity of an identified test. [pmid: 844672].
Scott B B, Goodall A, Stephenson P, et al. Small intestinal plasma cells in coeliac disease. Gut. 1984;25(1):41-46. Not sensitivity or specificity of an identified test. [pmid: 6360813]. [pmcid: 1432231].
Scott B B, Goodall A, Stephenson P, et al. Duodenal bulb plasma cells in duodenitis and duodenal ulceration. Gut. 1985;26(10):1032-1037. Not sensitivity or specificity of an identified test. [pmid: 3902587]. [pmcid: 1432942].
Scott B B, Hardy G J, Losowsky M S. Involvement of the small intestine in systemic mast cell disease. Gut. 1975;16(11):918-924. Not sensitivity or specificity of an identified test. [pmid: 273]. [pmcid: 1413129].
Scott B B, Losowsky M S, Rajah S M. Letter: HL-A8 and HL-A12 in coeliac disease. Lancet. 1974;2(7873):171. Not sensitivity or specificity of an identified test. [pmid: 4136791].
Scott B B, Scott D G, Losowsky M S. Jejunal mucosal immunoglobulins and complement in untreated coeliac disease. J Pathol. 1977;121(4):219-223. Not sensitivity or specificity of an identified test. [pmid: 327040].
Scott B B, Swinburne M L, Rajah S M, et al. HL A8 and the immune response to gluten. Lancet. 1974;2(7877):374-377. Not sensitivity or specificity of an identified test. [pmid: 4136791].
Scott B B, Young S, Rajah S M, et al. Coeliac disease and dermatitis herpetiformis: further studies of their relationship. Gut. 1976;17(10):759-762. Not sensitivity or specificity of an identified test. [pmid: 1001971]. [pmcid: 1411197].
Scott B B, Young S, Rajah S M, et al. Proceedings: The incidence of coeliac diseases and HL-A8 in dermatitis herpetiformis. Gut. 1975;16(10):845. Not sensitivity or specificity of an identified test. [pmid: 1205335].
Scott H, Brandtzaeg P, Solheim B G, et al. Relation between HLA-DR-like antigens and secretory component (SC) in jejunal epithelium of patients with coeliac disease or dermatitis herpetiformis. Clinical and Experimental Immunology. 1981;44(2):233-238. Not sensitivity or specificity of an identified test. [pmid: 7030531]. [pmcid: 1537331].
Scott H, Brandtzaeg P, Thorsby E, et al. Mucosal and systemic immune response patterns in celiac disease. Ann Allergy. 1983;51(2 Pt 2):233-239. Not sensitivity or specificity of an identified test. [pmid: 6603800].
Scott H, Ek J, Havnen J, et al. Serum antibodies to dietary antigens: a prospective study of the diagnostic usefulness in celiac disease of children. Journal of Pediatric Gastroenterology and Nutrition. 1990;11(2):215-220. Not sensitivity or specificity of an identified test. [pmid: 2395062].
Scott H, Fausa O, Thorsby E. T-lymphocyte activation by a gluten fraction, glyc-gli. Studies of adult coeliac patients and healthy controls. Scandinavian Journal of Immunology. 1983;18(3):185-191. Not sensitivity or specificity of an identified test. [pmid: 6604938].
Scott H, Fausa O, Ek J, et al. Measurements of serum IgA and IgG activities to dietary antigens. A prospective study of the diagnostic usefulness in adult coeliac disease. Scandinavian Journal of Gastroenterology. 1990;25(3):287-292. Not sensitivity or specificity of an identified test. [pmid: 2320948].
Scott H, Hirschberg H, Thorsby E. HLA-DR3- and HLA-DR7-restricted T-cell hyporesponsiveness to gluten antigen: a clue to the aetiology of coeliac disease?. Scand J Immunol. 1983;18(2):163-167. Not sensitivity or specificity of an identified test. [pmid: 6603652].
Scott H, Nilsen E, Sollid L M, et al. Immunopathology of gluten-sensitive enteropathy. Springer Semin Immunopathol. 1997;18(4):535-553. Not sensitivity or specificity of an identified test. [pmid: 9144869].
Scott H, Sollid L M, Brandtzaeg P et al. Jejunal epithelium of patients with coeliac disease shows enhanced expression of MHC class II subregion products. Adv Exp Med Biol 1988;237689–693. Not sensitivity or specificity of an identified test
Scott H, Sollid L M, Fausa O, et al. Expression of major histocompatibility complex class II subregion products by jejunal epithelium in patients with coeliac disease. Scandinavian Journal of Immunology. 1987;26(5):563-571. Not sensitivity or specificity of an identified test. [pmid: 3500504].
Scully L J, Toze C, Sengar D P S, et al. Early-onset autoimmune hepatitis is associated with a C4A gene deletion. Gastroenterology. 1993;104(5):1478-1484. Not sensitivity or specificity of an identified test. [pmid: 8482459].
Seah P P, Fry L, Holborow E J, et al. Antireticulin antibody: incidence and diagnostic significance. Gut. 1973;14(4):311-315. Not sensitivity or specificity of an identified test. [pmid: 4574903]. [pmcid: 1412607].
Seah P P, Fry L, Kearney J W, et al. A comparison of histocompatibility antigens in dermatitis herpetiformis and adult coeliac disease. British Journal of Dermatology. 1976;94(2):131-138. Not sensitivity or specificity of an identified test.
Sebus J, Fernandes J, van der, et al. A new twin hole capsule for peroral intestinal biopsy in children. Digestion. 1968;1(4):193-199. Not sensitivity or specificity of an identified test. [pmid: 5303250].
Segni M, Pani M A, Pasquino A M, et al. Familial clustering of juvenile thyroid autoimmunity: Higher risk is conferred by human leukocyte antigen DR3-DQ2 and thyroid peroxidase antibody status in fathers. J Clin Endocrinol Metab. 2002;87(8):3779-3782. Not sensitivity or specificity of an identified test. [pmid: 12161510].
Seissler J, Boms S, Wohlrab U, et al. Antibodies to human recombinant tissue transglutaminase measured by radioligand assay: evidence for high diagnostic sensitivity for celiac disease. Hormone and Metabolic Research. Hormon- Und Stoffwechselforschung. Hormones Et Metabolisme. 1999;31(6):375-379. Improper control group. [pmid: 10437627].
Seissler J, Wohlrab U, Wuensche C, et al. Autoantibodies from patients with coeliac disease recognize distinct functional domains of the autoantigen tissue transglutaminase. Clinical and Experimental Immunology. 2001;125(2):216-221. Not sensitivity or specificity of an identified test. [pmid: 11529912]. [pmcid: 1906132].
Seiving B, Ohlsson K, Linder C, et al. Transglutaminase differentiation during maturation of human blood monocytes to macrophages. European Journal of Haematology. 1991;46(5):263-271. Not sensitivity or specificity of an identified test. [pmid: 1675177].
Sela B-A. Homocysteine gets to the brain. Isr Med Assoc J. 2002;4(3):204-206. Not sensitivity or specificity of an identified test. [pmid: 12489510].
Selby R, Barnard J M, Buehler S K, et al. Tuberculosis associated with HLA--B8, BfS in a Newfoundland community study. Tissue Antigens. 1978;11(5):403-408. Not sensitivity or specificity of an identified test. [pmid: 694904].
Selby W. Gluten enteropathy. Aust Prescr. 2001;24(2):38-4047. Not sensitivity or specificity of an identified test.
Selby W S, Painter D, Collins A, et al. Persistent mucosal abnormalities in coeliac disease are not related to the ingestion of trace amounts of gluten. Scandinavian Journal of Gastroenterology. 1999;34(9):909-914. Not sensitivity or specificity of an identified test. [pmid: 10522611].
Seliger G, Goldman A B, Firooznia H, et al. Ulceration of the small intestine complicating celiac disease. American Journal of Digestive Diseases. 1973;18(9):820-824. Not sensitivity or specificity of an identified test. [pmid: 4725325].
Selzer G, Sherman G, Callihan T R, et al. Primary small intestinal lymphomas and alpha-heavy-chain disease. A study of 43 cases from a pathology department in Israel. Israel Journal of Medical Sciences. 1979;15(2):111-123. Not sensitivity or specificity of an identified test. [pmid: 112083].
Semenza G, Bircher J, Mulhaupt E et al. Arbutin absorption in human small intestine: a simple procedure for the determination of active sugar uptake in peroral biopsy specimens. Clinica Chimica Acta 1969;International Journal of Clinical Chemistry; 25(2):213–219. Not sensitivity or specificity of an identified test
Senarath Yapa R S. Coeliac disease in young and old patients. J Clin Exp Gerontol. 1991;13(3):95-102. Not sensitivity or specificity of an identified test.
Sengar D P S, Goldstein R. Comprehensive typing of DQB1 alleles by PCR-RFLP. Tissue Antigens. 1994;43(4):242-248. Not sensitivity or specificity of an identified test. [pmid: 7940497].
Serebrinsky G, Palermo M, Geffner J, et al. Opposite effects of amines on lymphocyte- and monocyte-mediated ADCC. International Journal of Immunopharmacology. 1988;10(5):555-561. Not sensitivity or specificity of an identified test. [pmid: 3145924].
Serjeantson S W, Court J, Mackay I R, et al. HLA-DQ genotypes are associated with autoimmunity to glutamic acid decarboxylase in insulin-dependent diabetes mellitus patients. Human Immunology. 1993;38(2):97-104. Not sensitivity or specificity of an identified test. [pmid: 8106272].
Serrano-Rios M, Gutierrez-Lopez M D, Perez-Bravo F, et al. HLA-DR, DQ and anti-GAD antibodies in first degree relatives of type I diabetes mellitus. Diabetes Res Clin Pract. 1996;34(Suppl):S133-S139. Not sensitivity or specificity of an identified test. [pmid: 9015682].
Shah V H, Rotterdam H, Kotler D P, et al. All that scallops is not celiac disease. Gastrointestinal Endoscopy. 2000;51(6):717-720. Not sensitivity or specificity of an identified test. [pmid: 10840307].
Shahbazkhani B, Forootan M, Merat S, et al. Coeliac disease presenting with symptoms of irritable bowel syndrome. Alimentary Pharmacology & Therapeutics. 2003;18(2):231-235. Not sensitivity or specificity of an identified test. [pmid: 12869084].
Shahbazkhani Bijan, Malekzadeh Reza, Sotoudeh Masoud, et al. High prevalence of coeliac disease in apparently healthy Iranian blood donors. European Journal of Gastroenterology & Hepatology. 2003;15(5):475-478. Not sensitivity or specificity of an identified test. [pmid: 12702902].
Shainoff J R, Urbanic D A. Multicolour immuno-staining of fibrinogen polypeptide chains for identification of their derivatives in electrophoregrams. Blood Coagulation & Fibrinolysis - an International Journal in Haemostasis and Thrombosis. 1990;1(45):479-484. Not sensitivity or specificity of an identified test. [pmid: 1983461].
Shainoff J R, Urbanic D A, DiBello P M. Immunoelectrophoretic characterizations of the cross-linking of fibrinogen and fibrin by factor XIIIa and tissue transglutaminase. Identification of a rapid mode of hybrid alpha-/gamma-chain cross-linking that is promoted by the gamma-chain cross-linking. Journal of Biological Chemistry. 1991;266(10):6429-6437. Not sensitivity or specificity of an identified test. [pmid: 1672529].
Shainoff J R, Valenzuela R, Urbanic D A, et al. Fibrinogen A alpha and gamma-chain dimers as potential differential indicators of atherosclerotic and thrombotic vascular disease. Blood Coagulation & Fibrinolysis - an International Journal in Haemostasis and Thrombosis. 1990;1(45):499-503. Not sensitivity or specificity of an identified test. [pmid: 1983461].
Shamir R, Shoenfeld Y, Blank M, et al. The prevalence of coeliac disease antibodies in patients with the antiphospholipid syndrome. Lupus. 2003;12(5):394-399. Not sensitivity or specificity of an identified test. [pmid: 12765303].
Shamir Raanan, Eliakim Rami, Lahat Nitza, et al. ELISA of anti-endomysial antibodies in the diagnosis of celiac disease: comparison with immunofluorescence assay of anti-endomysial antibodies and tissue transglutaminase antibodies. Israel Medical Association Journal - Imaj. 2002;4(8):594-596. Improper control group.
Shamir Raanan, Lerner Aaron, Shinar Eilat, et al. The use of a single serological marker underestimates the prevalence of celiac disease in Israel: a study of blood donors. American Journal of Gastroenterology. 2002;97(10):2589-2594. Not sensitivity or specificity of an identified test. [pmid: 12385444].
Shan Lu, Molberg Oyvind, Parrot Isabelle, et al. Structural basis for gluten intolerance in celiac sprue. Science. 2002;297(5590):2275-2279. Not sensitivity or specificity of an identified test. [pmid: 12351792].
Shanahan F, McKenna R, McCarthy C F, et al. Coeliac disease and diabetes mellitus: a study of 24 patients with HLA typing. Quarterly Journal of Medicine. 1982;51(203):329-335. Not sensitivity or specificity of an identified test. [pmid: 6755530].
Shand A G, Ciclitira P J. Celiac disease. Clin Perspect Gastroenterol. 2002;5(5):277-283. Not sensitivity or specificity of an identified test.
Shaoul R, Marcon M A, Okada Y, et al. Gastric metaplasia: a frequently overlooked feature of duodenal biopsy specimens in untreated celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 2000;30(4):397-403. Not sensitivity or specificity of an identified test. [pmid: 10776950].
Sheehan N J, Stanton-King K. Polyautoimmunity in a young woman. British Journal of Rheumatology. 1993;32(3):254-256. Not sensitivity or specificity of an identified test. [pmid: 8448621].
Sheldon W, Tempany E. Small intestine peroral biopsy in coeliac children. Gut. 1966;7(5):481-489. Improper control group. [pmid: 5929259]. [pmcid: 1552507].
Sherman S L. Genetic analysis workshop IV: summary for coeliac disease. Genetic Epidemiology.Supplement 1986;1271–276. Not sensitivity or specificity of an identified test
Sherman S L, Iselius L, Ellis A et al. Combined segregation and linkage analysis of coeliac disease. Genetic Epidemiology.Supplement 1986;1283–288. Not sensitivity or specificity of an identified test
Sherritt M A, Tait B, Varney M, et al. Immunosusceptibility genes in rheumatoid arthritis. Hum Immunol. 1996;51(1):32-40. Not sensitivity or specificity of an identified test. [pmid: 8911995].
Sheth K J, Werlin S L, Freeman M E, et al. Gastrointestinal structure and function in Fabry's disease. American Journal of Gastroenterology. 1981;76(3):246-251. Not sensitivity or specificity of an identified test. [pmid: 6274188].
Shibahara M, Nanko H, Shimizu M, et al. Dermatitis herpetiformis in Japan: An update. Dermatology. 2002;204(1):37-42. Not sensitivity or specificity of an identified test. [pmid: 11834848].
Shidrawi R G, Ciclitira P J. Celiac disease. Curr Opin Gastroenterol. 1996;12(2):159-163. Not sensitivity or specificity of an identified test.
Shidrawi R G, Day P, Przemioslo R, et al. In vitro toxicity of gluten peptides in coeliac disease assessed by organ culture. Scandinavian Journal of Gastroenterology. 1995;30(8):758-763. Not sensitivity or specificity of an identified test. [pmid: 7481543].
Shidrawi R G, Parnell N D, Ciclitira P J, et al. Binding of gluten-derived peptides to the HLA-DQ2 (alpha1*0501, beta1*0201) molecule, assessed in a cellular assay. Clinical and Experimental Immunology. 1998;111(1):158-165. Not sensitivity or specificity of an identified test. [pmid: 9472676]. [pmcid: 1904843].
Shidrawi R G, Przemioslo R, Davies D R, et al. Pitfalls in diagnosing coeliac disease. Journal of Clinical Pathology. 1994;47(8):693-694. Improper control group. [pmid: 7962617]. [pmcid: 502137].
Shih J-F, Hunninghake G W, Goeken N E, et al. The relationship between HLA-A, B, DQ, and DR antigens and asbestos- induced lung disease. Chest. 1993;104(1):26-31. Not sensitivity or specificity of an identified test. [pmid: 8325081].
Shimizu T, Beijer E, Strandvik B. Leukotriene B4 and C4 metabolism in small intestine mucosa of children with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1995;21(4):426-429. Not sensitivity or specificity of an identified test. [pmid: 8583294].
Shimizu T, Beijer E, Ryd W, et al. Leukotriene B4 and C4 generation by small intestinal mucosa in children with coeliac disease. Digestion. 1994;55(4):239-242. Not sensitivity or specificity of an identified test. [pmid: 8063028].
Shimoda S S, O'Brien T K, Saunders D R. Fat absorption after infusing bile salts into the human small intestine. Gastroenterology. 1974;67(1):7-18. Not sensitivity or specificity of an identified test. [pmid: 4366283].
Shiner M. Coeliac disease. Electron microscopy of jejunal mucosa. Clinics in Gastroenterology. 1974;3(1):33-53. Review article. [pmid: 4365851].
Shiner M. Ultrastructural changes suggestive of immune reactions in the jejunal mucosa of coeliac children following gluten challenge. Gut. 1973;14(1):1-12. Not sensitivity or specificity of an identified test. [pmid: 4758700]. [pmcid: 1412582].
Shiner M. Ultrastructural features of allergic manifestations in the small intestine of children. Scandinavian Journal of Gastroenterology.Supplement 1981;7049–64. Not sensitivity or specificity of an identified test
Shiner M. Electron microscopy of jejunal mucosa. Clin Gastroenterol. 1974;3(1):33-53. Not sensitivity or specificity of an identified test. [pmid: 4365851].
Shiner M, Shmerling D H. The immunopathology of coeliac disease. Digestion. 1972;5(2):69-88. Not sensitivity or specificity of an identified test. [pmid: 5007725].
Shiner R J, Ballard J. Mucosal secretory IgA and secretory piece in adult coeliac disease. Gut. 1973;14(10):778-783. Not sensitivity or specificity of an identified test. [pmid: 4758700]. [pmcid: 1412792].
Shipman R T, Williams A L, Kay R, et al. A family study of coeliac disease. Australian and New Zealand Journal of Medicine. 1975;5(3):250-255. Not sensitivity or specificity of an identified test. [pmid: 1057937].
Shitabata P K, Crouch E C, Fitzgibbon J F, et al. Cutaneous sclerotic fibroma. Immunohistochemical evidence of a fibroblastic neoplasm with ongoing type I collagen synthesis. American Journal of Dermatopathology. 1995;17(4):339-343. Not sensitivity or specificity of an identified test. [pmid: 8600796].
Shmakov A N, Bode J, Kilshaw P J, et al. Diverse patterns of expression of the 67-kD laminin receptor in human small intestinal mucosa: potential binding sites for prion proteins?. Journal of Pathology. 2000;191(3):318-322. Not sensitivity or specificity of an identified test. [pmid: 10878555].
Shmerling D H, Franckx J. Childhood celiac disease: a long-term analysis of relapses in 91 patients. Journal of Pediatric Gastroenterology and Nutrition. 1986;5(4):565-569. Not sensitivity or specificity of an identified test. [pmid: 3735007].
Shokrgozar M A, Shokri F. HLA-associated antibody response to recombinant hepatitis B vaccine in healthy Iranian adults. Iran J Med Sci. 1999;24(34):98-103. Not sensitivity or specificity of an identified test.
Shtauvere A, Rumba I, Dzivite I, et al. HLA-DR and -DQ gene polymorphism in Latvian patients with insulin-dependent diabetes mellitus. Tissue Antigens. 1998;52(4):385-388. Not sensitivity or specificity of an identified test. [pmid: 9820603].
Shtauvere-Brameus A, Dabadghao P, Rumba I et al. Tumor necrosis factor-alpha allele 2 shows an association with insulin-dependent diabetes mellitus in Latvians. Annals of the New York Academy of Sciences 2002;958357–361. Not sensitivity or specificity of an identified test
Shtauvere-Brameus A, Falorni A, Rumba I et al. Islet autoantibodies in Latvian subjects with non-insulin-dependent diabetes mellitus: slow-onset type 1 diabetes or polyendocrine autoimmunity?. Annals of the New York Academy of Sciences 2002;958259–262. Not sensitivity or specificity of an identified test
Shtauvere-Brameus A, Ghaderi M, Rumba I et al. Microsatellite allele 5 of MHC class I chain-related gene a increases the risk for insulin-dependent diabetes mellitus in latvians. Annals of the New York Academy of Sciences 2002;958349–352. Not sensitivity or specificity of an identified test
Shuster S, Watson A J, Marks J. Coeliac syndrome in dermatitis herpetiformis. Lancet. 1968;1(7552):1101-1106. Not sensitivity or specificity of an identified test. [pmid: 4171839].
Sidney John, del Guercio, Marie Southwood, et al. The HLA molecules DQA1*0501/B1*0201 and DQA1*0301/B1*0302 share an extensive overlap in peptide binding specificity. Journal of Immunology (Baltimore, Md.- 1950). 2002;169(9):5098-5108. Not sensitivity or specificity of an identified test.
Siebenlist K R, Mosesson M W. Evidence of intramolecular cross-linked A alpha.gamma chain heterodimers in plasma fibrinogen. Biochemistry. 1996;35(18):5817-5821. Not sensitivity or specificity of an identified test. [pmid: 8756701].
Siegel L M, Stevens P D, Lightdale C J, et al. Combined magnification endoscopy with chromoendoscopy in the evaluation of patients with suspected malabsorption. Gastrointestinal Endoscopy. 1997;46(3):226-230. Not sensitivity or specificity of an identified test. [pmid: 9378209].
Signer E, Burgin-Wolff A, Berger R, et al. Antibodies to gliadin as a screening test for coeliac disease. A prospective study. Helvetica Paediatrica Acta. 1979;34(1):41-52. Serology <1990. [pmid: 372144].
Signore A, Chianelli M, Annovazzi A, et al. Imaging active lymphocytic infiltration in coeliac disease with iodine-123-interleukin-2 and the response to diet. European Journal of Nuclear Medicine. 2000;27(1):18-24. Not sensitivity or specificity of an identified test. [pmid: 10654142].
Sigurs N, Johansson C, Elfstrand P O, et al. Prevalence of coeliac disease in diabetic children and adolescents in Sweden. Acta Paediatrica (Oslo, Norway - 1992). 1993;82(9):748-751. Not sensitivity or specificity of an identified test. [pmid: 8241671].
Silink M. How should we manage celiac disease in childhood diabetes?. Pediatr Diabetes. 2001;2(3):95-97. Not sensitivity or specificity of an identified test. [pmid: 15016190].
Silk D B A, Kumar P J, Perrett D. Amino acid and peptide absorption in patients with coeliac disease and dermatitis herpetiformis. Gut. 1974;15(1):1-8. Not sensitivity or specificity of an identified test. [pmid: 4820629]. [pmcid: 1412941].
Silk D B A, Kumar P J, Webb J P W. Ileal function in patients with untreated adult coeliac disease. Gut. 1975;16(4):261-267. Not sensitivity or specificity of an identified test. [pmid: 1132801]. [pmcid: 1410918].
Siltanen Mirjami, Kajosaari Merja, Savilahti Emma M, et al. IgG and IgA antibody levels to cow's milk are low at age 10 years in children born preterm. Journal of Allergy and Clinical Immunology. 2002;110(4):658-663. Not sensitivity or specificity of an identified test. [pmid: 12373277].
Silva E M, Fernandes M I, Galvao L C, et al. Human leukocyte antigen class II alleles in white Brazilian patients with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 2000;31(4):391-394. Improper control group. [pmid: 11045836].
Silva L M, Donadi E A. Is immunogenetic susceptibility to neuropsychiatric systemic lupus erythematosus (SLE) different from non-neuropsychiatric SLE?. Ann Rheum Dis. 1996;55(8):544-547. Not sensitivity or specificity of an identified test. [pmid: 8774183]. [pmcid: 1010235].
Silverman J S, Tamsen A. Mammary fibroadenoma and some phyllodes tumour stroma are composed of CD34+ fibroblasts and factor XIIIa+ dendrophages. Histopathology. 1996;29(5):411-419. Not sensitivity or specificity of an identified test. [pmid: 8951485].
Silvestris F, Anderson W, Goodwin J S, et al. Discrepancy in the expression of autoantibodies in healthy aged individuals. Clin Immunol Immunopathol. 1985;35(2):234-244. Not sensitivity or specificity of an identified test. [pmid: 3878247].
Simon M, Green H. Participation of membrane-associated proteins in the formation of the cross-linked envelope of the keratinocyte. Cell. 1984;36(4):827-834. Not sensitivity or specificity of an identified test. [pmid: 6200236].
Simon M, Haftek M, Sebbag M, et al. Evidence that filaggrin is a component of cornified cell envelopes in human plantar epidermis. Biochemical Journal. 1996;317(Pt 1):173-177. Not sensitivity or specificity of an identified test. [pmid: 8694761]. [pmcid: 1217460].
Simpson F G, Bullen A W, Robertson D A, et al. HLA-B8 and cell-mediated immunity to gluten. Gut. 1981;22(8):633-636. Not sensitivity or specificity of an identified test. [pmid: 6974678]. [pmcid: 1420066].
Simpson F G, Howdle P D, Robertson D A, et al. Jejunal biopsy and lymphocyte co-culture in coeliac disease. Scandinavian Journal of Gastroenterology. 1983;18(6):749-754. Not sensitivity or specificity of an identified test. [pmid: 6669939].
Simu G, Jung J, Vojth V, et al. Microscopic observations concerning the autoimmune response escalation into malignant lymphoma. Morphologie Et Embryologie. 1986;32(2):99-104. Not sensitivity or specificity of an identified test. [pmid: 2942772].
Sinclair D, Pearce C B, Saas M S L, et al. A comparative study of tissue transglutaminase antibodies and endomysium antibody immunofluorescence in routine clinical laboratory practice. Ann Clin Biochem. 2003;40(4):411-416. Improper control group. [pmid: 12880544].
Singer M A, Hortsch M, Goodman C S, et al. Annulin, a protein expressed at limb segment boundaries in the grasshopper embryo, is homologous to protein cross-linking transglutaminases. Dev Biol. 1992;154(1):143-159. Not sensitivity or specificity of an identified test. [pmid: 1358727].
Singer Steven M, Zainelli Gina M, Norlund Maryam A, et al. Transglutaminase bonds in neurofibrillary tangles and paired helical filament tau early in Alzheimer's disease. Neurochemistry International. 2002;40(1):17-30. Not sensitivity or specificity of an identified test. [pmid: 11738469].
Singh U S, Cerione R A. Biochemical effects of retinoic acid on GTP-binding Protein/Transglutaminases in HeLa cells. Stimulation of GTP-binding and transglutaminase activity, membrane association, and phosphatidylinositol lipid turnover. Journal of Biological Chemistry. 1996;271(44):27292-27298. Not sensitivity or specificity of an identified test. [pmid: 8910304].
Singh U S, Erickson J W, Cerione R A. Identification and biochemical characterization of an 80 kilodalton GTP-binding/transglutaminase from rabbit liver nuclei. Biochemistry. 1995;34(48):15863-15871. Not sensitivity or specificity of an identified test. [pmid: 7495818].
Singh U S, Kunar M T, Kao Y L, et al. Role of transglutaminase II in retinoic acid-induced activation of RhoA-associated kinase-2. Embo Journal. 2001;20(10):2413-2423. Not sensitivity or specificity of an identified test. [pmid: 11350930]. [pmcid: 125450].
Singh U S, Li Q, Cerione R. Identification of the eukaryotic initiation factor 5A as a retinoic acid-stimulated cellular binding partner for tissue transglutaminase II. Journal of Biological Chemistry. 1998;273(4):1946-1950. Not sensitivity or specificity of an identified test. [pmid: 9442029].
Singh Ugra S, Pan Jing, Kao Yu, et al. Tissue transglutaminase mediates activation of RhoA and MAP kinase pathways during retinoic acid-induced neuronal differentiation of SH-SY5Y cells. Journal of Biological Chemistry. 2002;278(1):391-399. Not sensitivity or specificity of an identified test. [pmid: 12401808].
Sinnott P J, Livieri C, Sampietro M, et al. CYP21/C4 gene organisation in Italian 21-hydroxylase deficiency families. Hum Genet. 1992;88(5):545-551. Not sensitivity or specificity of an identified test. [pmid: 1551657].
Sipos A, Csortos C, Sipka S, et al. The antigen/receptor specificity of antigranulocyte antibodies in patients with SLE. Immunology Letters. 1988;19(4):329-334. Not sensitivity or specificity of an identified test. [pmid: 2907509].
Sizemore N, Kasturi L, Gorodeski G et al. Retinoid regulation of human ectocervical epithelial cell transglutaminase activity and keratin gene expression. Differentiation 1993;Research in Biological Diversity; 54(3):219–225. Not sensitivity or specificity of an identified test
Sjoberg K, Eriksson S. Regional differences in coeliac disease prevalence in Scandinavia?. Scandinavian Journal of Gastroenterology. 1999;34(1):41-45. Not sensitivity or specificity of an identified test. [pmid: 10048731].
Sjoberg K, Alm R, Ivarsson S A, et al. Prevalence and clinical significance of gliadin antibodies in healthy children and adults. Scandinavian Journal of Gastroenterology. 1994;29(3):248-254. Improper control group. [pmid: 8209185].
Sjoberg K, Eriksson K F, Bredberg A, et al. Screening for coeliac disease in adult insulin-dependent diabetes mellitus. Journal of Internal Medicine. 1998;243(2):133-140. Not sensitivity or specificity of an identified test. [pmid: 9566642].
Sjoberg K, Eriksson S, Tenngart B, et al. Factor XIII and tissue transglutaminase antibodies in coeliac and inflammatory bowel disease. Autoimmunity. 2002;35(5):357-364. Not sensitivity or specificity of an identified test. [pmid: 12515290].
Sjoberg K, Lindgren S, Eriksson S. Frequent occurrence of non-specific gliadin antibodies in chronic liver disease. Endomysial but not gliadin antibodies predict coeliac disease in patients with chronic liver disease. Scandinavian Journal of Gastroenterology. 1997;32(11):1162-1167. Not sensitivity or specificity of an identified test. [pmid: 9399399].
Sjoberg K, Wassmuth R, Reichstetter S, et al. Gliadin antibodies in adult insulin-dependent diabetes--autoimmune and immunogenetic correlates. Autoimmunity. 2000;32(4):217-228. Not sensitivity or specificity of an identified test. [pmid: 11191281].
Sjolund K, Ekman R. Plasma motilin in untreated celiac disease. Peptides. 2003;24(3):483-486. Not sensitivity or specificity of an identified test. [pmid: 12732349].
Sjolund K, Alumets J, Berg N O, et al. Duodenal endocrine cells in adult coeliac disease. Gut. 1979;20(7):547-552. Not sensitivity or specificity of an identified test. [pmid: 385455]. [pmcid: 1412522].
Sjolund K, Alumets J, Berg N O, et al. Enteropathy of coeliac disease in adults: increased number of enterochromaffin cells the duodenal mucosa. Gut. 1982;23(1):42-48. Not sensitivity or specificity of an identified test. [pmid: 7056495]. [pmcid: 1419593].
Sjolund K, Hakanson R, Lundqvist G, et al. Duodenal somatostatin in coeliac disease. Scandinavian Journal of Gastroenterology. 1982;17(8):969-976. Not sensitivity or specificity of an identified test. [pmid: 6132442].
Sjostrom H, Lundin K E, Molberg O, et al. Identification of a gliadin T-cell epitope in coeliac disease: general importance of gliadin deamidation for intestinal T-cell recognition. Scandinavian Journal of Immunology. 1998;48(2):111-115. Not sensitivity or specificity of an identified test. [pmid: 9716100].
Sjostrom H, Noren O, Krasilnikoff P A, et al. Intestinal peptidases and sucrase in coeliac disease. Clin Chim Acta. 1981;109(1):53-58. Not sensitivity or specificity of an identified test. [pmid: 7008982].
Skeen M B. Neurologic manifestations of gastrointestinal disease. Neurol Clin. 2002;20(1):195-225. Not sensitivity or specificity of an identified test. [pmid: 11754307].
Skerritt J H, Devery J M, Penttila I A et al. Cellular and humoral responses in coeliac disease. 2. Protein extracts from different cereals. Clinica Chimica Acta 1991;International Journal of Clinical Chemistry; 204(1–3):109–122. Not sensitivity or specificity of an identified test
Skoglosa J, Falth-Magnusson K, Stenhammar L. Conscious or deep sedation: a questionnaire regarding the experience of parents, children and staff during small bowel biopsy. Acta Paediatrica (Oslo, Norway - 1992). 2003;92(6):704-708. Not sensitivity or specificity of an identified test. [pmid: 12856982].
Skovbjerg H, Sjostrom H, Noren O B. Coeliac disease - A diagnostic and scientific challenge. Ugeskr Laeg. 2002;164(25):3329-3333. Not sensitivity or specificity of an identified test. [pmid: 12107945].
Slavin G, Sowter C, Robertson K, et al. Measurement in jejunal biopsies by computer-aided microscopy. Journal of Clinical Pathology. 1980;33(3):254-261. Not sensitivity or specificity of an identified test. [pmid: 7381024]. [pmcid: 1146049].
Slavin R G, Hutcheson P S, Chauhan B, et al. New insights into the pathogenesis of allergic bronchopulmonary aspergillosis. Allergy Clin Immunol Int. 2003;15(2):79-81. Not sensitivity or specificity of an identified test.
Slavutsky I, Gomez J C, Pedreira S, et al. Increased rDNA transcriptional activity in celiac disease. Journal of Clinical Gastroenterology. 1992;14(1):11-14. Not sensitivity or specificity of an identified test. [pmid: 1556401].
Sleisenger M H, Brandborg L L. Malabsorption. Major Problems in Internal Medicine 1977;13v–x,1–261. Not sensitivity or specificity of an identified test
Smecuol E, Bai J C, Vazquez H, et al. Gastrointestinal permeability in celiac disease. Gastroenterology. 1997;112(4):1129-1136. Not sensitivity or specificity of an identified test. [pmid: 9097995].
Smecuol E, Vazquez H, Sugai E, et al. Sugar tests detect celiac disease among first-degree relatives. American Journal of Gastroenterology. 1999;94(12):3547-3552. Not sensitivity or specificity of an identified test. [pmid: 10606317].
Smethurst P A, Griffin M. Measurement of tissue transglutaminase activity in a permeabilized cell system: its regulation by Ca2+ and nucleotides. Biochemical Journal. 1996;313(Pt 3):803-808. Not sensitivity or specificity of an identified test. [pmid: 8611158]. [pmcid: 1216981].
Smith A D, Bagheri B, Streilein R D, et al. Expression of interleukin-4 and interferon-gamma in the small bowel of patients with dermatitis herpetiformis and isolated gluten-sensitive enteropathy. Digestive Diseases and Sciences. 1999;44(10):2124-2132. Not sensitivity or specificity of an identified test. [pmid: 10548367].
Smith K, Mezebish D, Williams J P, et al. Cutaneous epithelioid schwannomas: A rare variant of a benign peripheral nerve sheath tumor. J Cutaneous Pathol. 1998;25(1):50-55. Not sensitivity or specificity of an identified test.
Smith M E, Costa M J, Weiss S W. Evaluation of CD68 and other histiocytic antigens in angiomatoid malignant fibrous histiocytoma. American Journal of Surgical Pathology. 1991;15(8):757-763. Not sensitivity or specificity of an identified test. [pmid: 1676879].
Smith S. Jejunal biopsy--seeking an alternative. Paediatric Nursing. 1996;8(4):17-19. Not sensitivity or specificity of an identified test. [pmid: 8716795].
Smith S E, Littlewood J M. The two-film barium meal in the exclusion of coeliac disease. Clinical Radiology. 1977;28(6):629-634. Not sensitivity or specificity of an identified test. [pmid: 589918].
Smoller B R, Apfelberg D B. Infantile (juvenile) capillary hemangioma: a tumor of heterogeneous cellular elements. Journal of Cutaneous Pathology. 1993;20(4):330-336. Not sensitivity or specificity of an identified test. [pmid: 7693777].
Smyth C, Kelleher D, Keeling P W N. Hepatic manifestations of gastrointestinal diseases inflammatory bowel disease, Celiac disease, and Whipple's disease. Clin Liver Dis. 2002;6(4):1013-1032. Not sensitivity or specificity of an identified test. [pmid: 12516204].
Snijders A, Elferink D G, Geluk A, et al. An HLA-DRB1-derived peptide associated with protection against rheumatoid arthritis is naturally processed by human APCsSUP1. J Immunol. 2001;166(8):4987-4993. Not sensitivity or specificity of an identified test. [pmid: 11290778].
Sobel J H, Trakht I, Wu H Q, et al. Alpha-Chain cross-linking in fibrin(ogen) Marburg. Blood. 1995;86(3):989-1000. Not sensitivity or specificity of an identified test. [pmid: 7620190].
Solheim B G, Ek J, Thune P O, et al. HLA antigens in dermatitis herpetiformis and coeliac disease. Tissue Antigens. 1976;7(1):57-59. Not sensitivity or specificity of an identified test. [pmid: 56060].
Sollid L M. Molecular basis of celiac disease. Annual Review of Immunology 2000;1853–81. Not sensitivity or specificity of an identified test
Sollid L M. Genetics of the immune response to gluten in coeliac disease. Digestive Diseases (Basel, Switzerland). 1998;16(6):345-347. Review article. [pmid: 10207220].
Sollid L M. Breast milk against coeliac disease. Gut. 2002;51(6):767-768. Not sensitivity or specificity of an identified test. [pmid: 12427772]. [pmcid: 1773451].
Sollid L M, Lundin K E. Coeliac disease. An inappropriate immune response. Lancet. 2001;358(Suppl):s13Not sensitivity or specificity of an identified test. [pmid: 11784562].
Sollid L M, Scott H. New tool to predict celiac disease on its way to the clinics. Gastroenterology. 1998;115(6):1584-1586. Not sensitivity or specificity of an identified test. [pmid: 9834289].
Sollid L M, Thorsby E. The primary association of celiac disease to a given HLA-DQ alpha/beta heterodimer explains the divergent HLA-DR associations observed in various Caucasian populations. Tissue Antigens. 1990;36(3):136-137. Not sensitivity or specificity of an identified test. [pmid: 2278049].
Sollid L M, Thorsby E. HLA susceptibility genes in celiac disease: genetic mapping and role in pathogenesis. Gastroenterology. 1993;105(3):910-922. Review article. [pmid: 8359659].
Sollid L M, Markussen G, Ek J, et al. Evidence for a primary association of celiac disease to a particular HLA-DQ alpha/beta heterodimer. Journal of Experimental Medicine. 1989;169(1):345-350. Improper control group. [pmid: 2909659].
Sollid L M, McAdam S N, Molberg O, et al. Genes and environment in celiac disease. Acta Odontologica Scandinavica. 2001;59(3):183-186. Not sensitivity or specificity of an identified test. [pmid: 11501889].
Sollid L M, Molberg O, McAdam S, et al. Autoantibodies in coeliac disease: tissue transglutaminase--guilt by association?. Gut. 1997;41(6):851-852. Not sensitivity or specificity of an identified test. [pmid: 9462222]. [pmcid: 1891617].
Sollid L M, Scott H, Kolberg J, et al. Serum antibodies to wheat germ agglutinin and gluten in patients with dermatitis herpetiformis. Archives of Dermatological Research. 1986;278(6):433-436. Not sensitivity or specificity of an identified test. [pmid: 3789802].
Sollid L, Bruserud O, Gaudernack G, et al. The role of the CD8-positive subset of T cells in proliferative responses to soluble antigens. I. Studies of healthy subjects, type 1 diabetics, and coeliac disease patients. Scandinavian Journal of Immunology. 1986;23(4):461-467. Not sensitivity or specificity of an identified test. [pmid: 3010444].
Sollid L, Scott H, Thorsby E. Suppressor-cell activity in coeliac disease. Lancet. 1985;1(8422):229-230. Not sensitivity or specificity of an identified test. [pmid: 2857313].
Sollid Ludvig M. Coeliac disease: dissecting a complex inflammatory disorder. Nature Reviews. Immunology 2002;2(9):647-655. Not sensitivity or specificity of an identified test.
Soltoft J. Immunoglobulin-containing cells in non-tropical sprue. Clinical and Experimental Immunology. 1970;6(3):413-420. Not sensitivity or specificity of an identified test. [pmid: 4193742]. [pmcid: 1712693].
Soltoft J, Weeke B. Immunoglobulins in serum and jejunal biopsies in non-tropical sprue. Acta Medica Scandinavica. 1969;186(5):459-464. Not sensitivity or specificity of an identified test. [pmid: 4907873].
Song Y C, Sheng D, Taubenfeld S M, et al. A microtiter assay for factor XIII using fibrinogen and biotinylcadaverine as substrates. Analytical Biochemistry. 1994;223(1):88-92. Not sensitivity or specificity of an identified test. [pmid: 7695107].
Song Y, Taubenfeld S M, Sheng D, et al. Characterization of a monoclonal antibody directed against the carboxyl-terminus of human factor XIII. An epitope exposed upon denaturation and conserved across species lines. Thrombosis and Haemostasis. 1994;71(1):62-67. Not sensitivity or specificity of an identified test. [pmid: 7513094].
Sorell L, Garrote J A, Acevedo B, et al. One-step immunochromatographic assay for screening of coeliac disease. Lancet. 2002;359(9310):945-946. Improper control group. [pmid: 11918916].
Soresi M, Amplo M, Agliastro R, et al. Screening for autoantibodies to tissue transglutaminase reveals a low prevalence of celiac disease in blood donors with cryptogenic hypertransaminasemia. Digestion. 2001;64(2):87-91. Not sensitivity or specificity of an identified test. [pmid: 11684821].
Sorg C, Michels E, Malorny U, et al. Migration inhibitory factors and macrophage differentiation. Springer Seminars in Immunopathology. 1984;7(4):311-320. Not sensitivity or specificity of an identified test. [pmid: 6395408].
Sottrup-Jensen L, Stepanik T M, Kristensen T. Primary structure of human alphainf 2-macroglobulin. V. The complete structure. J Biol Chem. 1984;259(13):8318-8327. Not sensitivity or specificity of an identified test. [pmid: 6203908].
Souroujon M, Ashkenazi A, Lupo M, et al. Serum ferritin levels in celiac disease. American Journal of Clinical Pathology. 1982;77(1):82-86. Not sensitivity or specificity of an identified test. [pmid: 7055099].
Spencer J, MacDonald T T, Diss T C, et al. Changes in intraepithelial lymphocyte subpopulations in coeliac disease and enteropathy associated T cell lymphoma (malignant histiocytosis of the intestine). Gut. 1989;30(3):339-346. Not sensitivity or specificity of an identified test. [pmid: 2785074]. [pmcid: 1378456].
Spiekerkoetter U, Seissler J, Wendel U. General screening for celiac disease is advisable in children with type 1 diabetes. Hormone and Metabolic Research.Hormon- Und Stoffwechselforschung. Hormones Et Metabolisme. 2002;34(4):192-195. Not sensitivity or specificity of an identified test. [pmid: 11987028].
Spurkland A, Ingvarsson G, Falk E S, et al. Dermatitis herpetiformis and celiac disease are both primarily associated with the HLA-DQ (alpha 1*0501, beta 1*02) or the HLA-DQ (alpha 1*03, beta 1*0302) heterodimers. Tissue Antigens. 1997;49(1):29-34. Improper control group. [pmid: 9027962].
Spurkland A, Sollid L M, Polanco I, et al. HLA-DR and -DQ genotypes of celiac disease patients serologically typed to be non-DR3 or non-DR5/7. Human Immunology. 1992;35(3):188-192. Not sensitivity or specificity of an identified test. [pmid: 1293082].
Spurkland A, Sollid L M, Ronningen K S, et al. Susceptibility to develop celiac disease is primarily associated with HLA-DQ alleles. Human Immunology. 1990;29(3):157-165. Improper control group. [pmid: 1980918].
Srinivasan U, Jones E, Weir D G, et al. Lactase enzyme, detected immunohistochemically, is lost in active celiac disease, but unaffected by oats challenge. American Journal of Gastroenterology. 1999;94(10):2936-2941. Not sensitivity or specificity of an identified test. [pmid: 10520848].
Stachowski J, Kramer J, Fust G, et al. Relationship between the reactivity to hepatitis B virus vaccination and the frequency of MHC class I, II and III alleles in haemodialysis patients. Scand J Immunol. 1995;42(1):60-65. Not sensitivity or specificity of an identified test. [pmid: 7631146].
Stachowski J, Pollok M, Barth C, et al. Non-responsiveness to hepatitis B vaccination in haemodialysis patients: Association with impaired TCR/CD3 antigen receptor expression regulating co-stimulatory processes in antigen presentation and recognition. Nephrol Dial Transplant. 1994;9(2):144-152. Not sensitivity or specificity of an identified test. [pmid: 7910675].
Stahlberg M R, Savilahti E, Viander M. Antibodies to gliadin by ELISA as a screening test for childhood celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1986;5(5):726-729. Serology <1990. [pmid: 3761105].
Stallmach A, Belitz H D, Gellermann B, et al. Effects of gliadin peptides B1–B4 in celiac disease. I. Organ culture studies. Journal of Pediatric Gastroenterology and Nutrition. 1987;6(3):335-340. Not sensitivity or specificity of an identified test. [pmid: 3430242].
Stancu M, De Petris G, Palumbo T P, et al. Collagenous gastritis associated with lymphocytic gastritis and celiac disease. Arch Pathol Lab Med. 2001;125(12):1579-1584. Not sensitivity or specificity of an identified test. [pmid: 11735694].
Stankovic I, Miletic I, Djordjevic B. Determination of anti-secalin antibodies in sera from coeliac patients by ELISA-based assay. J Pharm Biomed Anal. 1998;18(12):255-261. Not sensitivity or specificity of an identified test. [pmid: 9863966].
Stark H J, Baur M, Breitkreutz D, et al. Organotypic keratinocyte cocultures in defined medium with regular epidermal morphogenesis and differentiation. Journal of Investigative Dermatology. 1999;112(5):681-691. Not sensitivity or specificity of an identified test. [pmid: 10233757].
Stark K L, Harris C, Juchau M R. Embryotoxicity elicited by inhibition of gamma-glutamyltransferase by acivicin and transferase antibodies in cultured rat embryos. Toxicol Appl Pharmacol. 1987;89(1):88-96. Not sensitivity or specificity of an identified test. [pmid: 2884755].
Staun M, Jarnum S. Measurement of the 10,000-molecular weight calcium-binding protein in small-intestinal biopsy specimens from patients with alabsorption syndromes. Scandinavian Journal of Gastroenterology. 1988;23(7):827-832. Not sensitivity or specificity of an identified test. [pmid: 3227298].
Steele J C, Young S P, Goodall J C, et al. Structural aspects of the interaction between heterogeneic human papillomavirus type 1 E4-specific T cell receptors and the same peptide/HLA- DQ8 complex. J Immunol. 1998;161(9):4745-4752. Not sensitivity or specificity of an identified test. [pmid: 9794405].
Steele R J C, Brown M, Eremin O. Characterisation of macrophages infiltrating human mammary carcinomas. Br J Cancer. 1985;51(1):135-138. Not sensitivity or specificity of an identified test. [pmid: 3155620].
Steffan J S, Thompson L M. Targeting aggregation in the development of therapeutics for the treatment of Huntington's disease and other polyglutamine repeat diseases. Expert Opin Ther Targets. 2003;7(2):201-213. Not sensitivity or specificity of an identified test. [pmid: 12667098].
Steinert P M, Marekov L N. Initiation of assembly of the cell envelope barrier structure of stratified squamous epithelia. Molecular Biology of the Cell. 1999;10(12):4247-4261. Not sensitivity or specificity of an identified test. [pmid: 10588656]. [pmcid: 25756].
Stene L C, Magnus P, Ronningen K S, et al. Diabetes-associated HLA-DQ genes and birth weight. Diabetes. 2001;50(12):2879-2882. Not sensitivity or specificity of an identified test. [pmid: 11723075].
Stenhammar L. Transient gastro-intestinal disorders during infancy and early childhood. A follow-up study with special reference to coeliac disease. Acta Paediatrica Scandinavica. 1981;70(3):383-387. Not sensitivity or specificity of an identified test. [pmid: 7246130].
Stenhammar L, Johansson C G. The incidence of coeliac disease in children in south-east Sweden. Acta Paediatrica Scandinavica. 1981;70(3):379-381. Not sensitivity or specificity of an identified test. [pmid: 7246129].
Stenhammar L, Ascher H, Danielsson L, et al. Small bowel biopsy in Swedish paediatric clinics. Acta Paediatrica (Oslo, Norway - 1992). 2002;91(10):1126-1129. Not sensitivity or specificity of an identified test. [pmid: 12434901].
Stenhammar L, Brandt A, Wagermark J. A family study of coeliac disease. Acta Paediatr Scand. 1982;71(4):625-628. Not sensitivity or specificity of an identified test. [pmid: 7136679].
Stenhammar L, Fallstrom S P, Jansson G, et al. Coeliac disease in children of short stature without gastrointestinal symptoms. European Journal of Pediatrics. 1986;145(3):185-186. Not sensitivity or specificity of an identified test. [pmid: 3769972].
Stenhammar L, FalthMagnusson K, Jansson G, et al. Intestinal permeability to inert sugars and different-sized polyethyleneglycols in children with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1989;9(3):281-289. Not sensitivity or specificity of an identified test. [pmid: 2614613].
Stenhammar L, Kilander A F, Nilsson L A, et al. Serum gliadin antibodies for detection and control of childhood coeliac disease. Acta Paediatrica Scandinavica. 1984;73(5):657-663. Serology <1990. [pmid: 6485785].
Stenhammar L, Stromberg L, Kilander A F, et al. Plasma enteroglucagon in the control of childhood celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1985;4(2):325-330. Not sensitivity or specificity of an identified test. [pmid: 3989631].
Stenhammar L, Warngard O, Lewander P, et al. Oral versus intravenous premedication for small bowel biopsy in children: effect on procedure and fluoroscopy times. Acta Paediatrica (Oslo, Norway - 1992). 1993;82(1):49-51. Not sensitivity or specificity of an identified test. [pmid: 8453221].
Stenling R, Fredrikzon B, Engberg S, et al. Surface ultrastructure of the small intestine mucosa in children with celiac disease. I. Untreated disease and effects of long-term gluten elimination and challenge. Ultrastructural Pathology. 1984;6(4):295-305. Not sensitivity or specificity of an identified test. [pmid: 6485122].
Stern M. Comparative evaluation of serologic tests for celiac disease: a European initiative toward standardization. Journal of Pediatric Gastroenterology and Nutrition. 2000;31(5):513-519. Improper control group. [pmid: 11144436].
Stern M. Concepts in coeliac disease: is there a receptor for gliadin?. Klinische Padiatrie. 1985;197(4):349-354. Not sensitivity or specificity of an identified test. [pmid: 3876477].
Stern M, Dietrich R. Gliadin- and immunoglobulin-containing cells of small intestinal lamina propria in childhood coeliac disease. European Journal of Pediatrics. 1982;139(1):13-17. Not sensitivity or specificity of an identified test. [pmid: 6759132].
Stern M, Bender S W, Gruttner R, et al. Serum antibodies against gliadin and reticulin in a family study of coeliac disease. European Journal of Pediatrics. 1980;135(1):31-36. Not sensitivity or specificity of an identified test. [pmid: 7004874].
Stern M, Dietrich R, Muller J. Small intestinal mucosa in coeliac disease and cow's milk protein intolerance: morphometric and immunofluorescent studies. European Journal of Pediatrics. 1982;139(2):101-105. Not sensitivity or specificity of an identified test. [pmid: 6759132].
Stern M, Fischer K, Gruettner R. Gliadin antibodies in coeliac disease. Acta Paediatr Belg. 1977;30(4):252. Not sensitivity or specificity of an identified test.
Stern M, Fischer K, Gruttner R. Immunofluorescent serum gliadin antibodies in children with coeliac disease and various malabsorptive disorders. II. Specificity of Gliadin antibodies: immunoglobulin classes, immunogenic properties of wheat protein fractions, and pathogenic significance of food antibodies in coeliac disease. European Journal of Pediatrics. 1979;130(3):165-172. Serology <1990. [pmid: 369862].
Stern M, Fischer K, Gruttner R. Immunofluorescent serum gliadin antibodies in children with coeliac disease and various malabsorptive disorders. I. Technique, clinical evaluation and diagnostic use of a gliadin antibody assay using pyruvic aldehyde-treated human red cells. European Journal of Pediatrics. 1979;130(3):155-164. Serology <1990. [pmid: 369862].
Stern M, Teuscher M, Wechmann T. Serological screening for coeliac disease: methodological standards and quality control Acta paediatrica (Oslo, Norway : 1992). Supplement. 1996:41249-51. Improper control group.
Stevens F M. Endoscopic dye-spraying in the diagnosis of coeliac disease. Acta Endosc. 1978;8(3):173-180. Not sensitivity or specificity of an identified test.
Stevens F M, Hitchcock H T. Farmer's lung disease and coeliac disease: A prospective study. Ir J Med Sci. 1977;146(10):335-339. Not sensitivity or specificity of an identified test. [pmid: 591277].
Stevens F M, McCarthy C F. The endoscopic demonstration of coeliac disease. Endoscopy. 1976;8(4):177-180. Not sensitivity or specificity of an identified test. [pmid: 1026384].
Stevens F M, Kearns M C, McCarthy C F. Abnormal pancreolauryl tests in coeliac disease: lack of correlation with the degree of intestinal mucosal damage. Journal of Clinical Pathology. 1997;50(12):1001-1004. Not sensitivity or specificity of an identified test. [pmid: 9516881]. [pmcid: 500380].
Stevens F M, Lloyd R S, Geraghty S M, et al. Schizophrenia and coeliac disease--the nature of the relationship. Psychological Medicine. 1977;7(2):259-263. Not sensitivity or specificity of an identified test. [pmid: 877189].
Stevens F M, Lloyd R, Egan-Mitchell B, et al. Proceedings: Anitreticulin antibodies in coeliacs and their relatives. Gut. 1973;14(10):829. Not sensitivity or specificity of an identified test. [pmid: 4758701].
Stevens F M, Lloyd R, Egan-Mitchell B, et al. Reticulin antibodies in patients with coeliac disease and their relatives. Gut. 1975;16(8):598-602. Not sensitivity or specificity of an identified test. [pmid: 1102397]. [pmcid: 1411013].
Stevens H Y, Reeve J, Noble B S. Bcl-2, tissue transglutaminase and p53 protein expression in the apoptotic cascade in ribs of premature infants. Journal of Anatomy. 2000;196(Pt 2):181-191. Not sensitivity or specificity of an identified test. [pmid: 10739014]. [pmcid: 1468052].
Stewart J. Child coeliacs in adult life. Ir Med J. 1974;67(15):411-414. Not sensitivity or specificity of an identified test. [pmid: 4412415].
Stewart J S. Clinical and morphologic response to gluten withdrawal. Clinics in Gastroenterology. 1974;3(1):109-126. Not sensitivity or specificity of an identified test. [pmid: 4600387].
Stewart J S, Pollock D J, Hoffbrand A V, et al. A study of proximal and distal intestinal structure and absorptive function in idiopathic steatorrhoea. Quarterly Journal of Medicine. 1967;36(143):425-444. Not sensitivity or specificity of an identified test. [pmid: 6049768].
Stewart W W, Kerr M A. The measurement of respiratory burst induced in polymorphonuclear neutrophils by IgA and IgG anti-gliadin antibodies isolated from coeliac serum. Immunology. 1991;73(4):491-497. Not sensitivity or specificity of an identified test. [pmid: 1916900]. [pmcid: 1384582].
Stockmann A, Hess S, Declerck P, et al. Multimeric vitronectin. Identification and characterization of conformation-dependent self-association of the adhesive protein. Journal of Biological Chemistry. 1993;268(30):22874-22882. Not sensitivity or specificity of an identified test. [pmid: 7693680].
Stokes P L, Holmes G K T. Malignancy. Clin Gastroenterol. 1974;3(1):159-170. Not sensitivity or specificity of an identified test.
Stokes P L, Asquith P, Cooke W T. Genetics of coeliac disease. Clin Gastroenterol. 1973;2(3):547-556. Not sensitivity or specificity of an identified test.
Stokes P L, Asquith P, Holmes G K, et al. Inheritance and influence of histocompatibility (HL-A) antigens in adult coeliac disease. Gut. 1973;14(8):627-630. Not sensitivity or specificity of an identified test. [pmid: 4743492]. [pmcid: 1412749].
Stokes P L, Ferguson R, Holmes G K, et al. Familial aspects of coeliac disease. Quarterly Journal of Medicine. 1976;45(180):567-582. Not sensitivity or specificity of an identified test. [pmid: 1005655].
Stokes P L, Holmes G K, Smits B J. Immunoglobulin levels in families with coeliac disease. Lancet. 1972;2(7777):608. Not sensitivity or specificity of an identified test. [pmid: 4115790].
Stone O J. Dermatitis herpetiformis and gluten sensitive enteropathy (including celiac disease)--increased subepithelial extracellular matrix viscosity due to gliadin. Medical Hypotheses. 1990;33(4):283-288. Not sensitivity or specificity of an identified test. [pmid: 2090932].
Storm W. Prevalence and diagnostic significance of gliadin antibodies in children with Down syndrome. European Journal of Pediatrics. 1990;149(12):833-834. Not sensitivity or specificity of an identified test. [pmid: 2146127].
Storsrud S, Olsson M, Arvidsson Lenner R, et al. Adult coeliac patients do tolerate large amounts of oats. European Journal of Clinical Nutrition. 2003;57(1):163-169. Not sensitivity or specificity of an identified test. [pmid: 12548312].
Straumfors A, Johansen B H, Vartdal F, et al. A peptide-binding assay for the disease-associated HLA-DQ8 molecule. Scandinavian Journal of Immunology. 1998;47(6):561-567. Not sensitivity or specificity of an identified test. [pmid: 9652824].
Streb H, Posselt H G, Wolter K, et al. Aldolase activities of the small intestinal mucosa in malabsorption states and hereditary fructose intolerance. European Journal of Pediatrics. 1981;137(1):5-10. Not sensitivity or specificity of an identified test. [pmid: 7274301].
Strobel S, Brydon W G, Ferguson A. Cellobiose/mannitol sugar permeability test complements biopsy histopathology in clinical investigation of the jejunum. Gut. 1984;25(11):1241-1246. Not sensitivity or specificity of an identified test. [pmid: 6437913]. [pmcid: 1432305].
Strobel S, Busuttil A, Ferguson A. Human intestinal mucosal mast cells: expanded population in untreated coeliac disease. Gut. 1983;24(3):222-227. Unable to extract data. [pmid: 6826106]. [pmcid: 1419930].
Strober W. Genetic and anthropologic factors in gluten-sensitive enteropathy. American Journal of Physical Anthropology. 1983;62(1):119-126. Not sensitivity or specificity of an identified test. [pmid: 6624897].
Strober W. Gluten-sensitive enteropathy. Clinics in Gastroenterology. 1976;5(2):429-452. Not sensitivity or specificity of an identified test. [pmid: 798646].
Strober W, Falchuk Z M, Rogentine G N, et al. The pathogenesis of gluten-sensitive enteropathy. Annals of Internal Medicine. 1975;83(2):242-256. Not sensitivity or specificity of an identified test. [pmid: 1170802].
Strocchi A, Corazza G, Furne J, et al. Measurements of the jejunal unstirred layer in normal subjects and patients with celiac disease. American Journal of Physiology. 1996;270(3 Pt 1):G487-G491. Not sensitivity or specificity of an identified test. [pmid: 8638715].
Strupp M. The humoral response in the pathogenesis of “gluten ataxia”. J Neurol. 2002;249(6):791-792. Not sensitivity or specificity of an identified test. [pmid: 12420718].
Stuart B M, Gent A E. Atrophy of the coeliac mucosa. European Journal of Gastroenterology & Hepatology. 1998;10(6):523-525. Not sensitivity or specificity of an identified test. [pmid: 9855071].
Stuber E, Buschenfeld A, Luttges J, et al. The expression of OX40 in immunologically mediated diseases of the gastrointestinal tract (celiac disease, Crohn's disease, ulcerative colitis). Eur J Clin Invest. 2000;30(7):594-599. Not sensitivity or specificity of an identified test. [pmid: 10886299].
Stuber Eckhard, Noth Rainer, Dirks Maren, et al. The role of tissue transglutaminase (transglutaminase type II) for the intestinal manifestations of murine semi-allogenic graft-versus-host disease. Journal of Autoimmunity. 2002;18(1):1-8. Not sensitivity or specificity of an identified test. [pmid: 11869041].
Stulik J, Hernychova L, Porkertova S, et al. Identification of new celiac disease autoantigens using proteomic analysis. Proteomics. 2003;3(6):951-956. Not sensitivity or specificity of an identified test. [pmid: 12833519].
Sturgess R, Ciclitira P J. Pathogenesis and pathophysiology of celiac disease. Curr Opin Gastroenterol. 1993;9(2):242-245. Not sensitivity or specificity of an identified test.
Sturgess R P, Hooper L B, Spencer J, et al. Effects of interferon-gamma and tumour necrosis factor-alpha on epithelial HLA class-II expression on jejunal mucosal biopsy specimens cultured in vitro. Scandinavian Journal of Gastroenterology. 1992;27(11):907-911. Not sensitivity or specificity of an identified test. [pmid: 1455186].
Sturgess R P, Macartney J C, Makgoba M W, et al. Differential upregulation of intercellular adhesion molecule-1 in coeliac disease. Clinical and Experimental Immunology. 1990;82(3):489-492. Not sensitivity or specificity of an identified test. [pmid: 1979938]. [pmcid: 1535517].
Sturgess R, Day P, Ellis H J, et al. Wheat peptide challenge in coeliac disease. Lancet. 1994;343(8900):758-761. Not sensitivity or specificity of an identified test. [pmid: 7907731].
Subramanian V S, Krishnaswami C V, Damodaran C. HLA, ESD, GLOI, C3 and HP polymorphisms and juvenile insulin dependent diabetes mellitus in Tamil Nadu (South India). Diabetes Res Clin Pract. 1994;25(1):51-59. Not sensitivity or specificity of an identified test. [pmid: 7835212].
Suedhoff T, Birckbichler P J, Lee K N, et al. Differential expression of transglutaminase in human erythroleukemia cells in response to retinoic acid. Cancer Research. 1990;50(24):7830-7834. Not sensitivity or specificity of an identified test. [pmid: 1979250].
Sueur R, Cerf M, Di Costanzo G, et al. Quantitative studies in vitro on uptake and esterification of palmitate into human and rat jejunal mucosa. Digestion. 1977;15(1):34-42. Not sensitivity or specificity of an identified test. [pmid: 838176].
Sugai E, Selvaggio G, Vazquez H, et al. Tissue transglutaminase antibodies in celiac disease: assessment of a commercial kit. American Journal of Gastroenterology. 2000;95(9):2318-2322. Improper control group. [pmid: 11007235].
Sugai Emilia, Chernavsky Alejandra, Pedreira Silvia, et al. Bone-specific antibodies in sera from patients with celiac disease: characterization and implications in osteoporosis. Journal of Clinical Immunology. 2002;22(6):353-362. Not sensitivity or specificity of an identified test. [pmid: 12462335].
Sugden P, Andrew J G, Andrew S M, et al. Dermal dendrocytes in Dupuytren's disease: a link between the skin and pathogenesis?. Journal of Hand Surgery (Edinburgh, Lothian). 1993;18(5):662-666. Not sensitivity or specificity of an identified test. [pmid: 7905015].
Suharjono. Intestinal biopsy and coeliac disease. Paediatrica Indonesiana. 1971;11(3):116-134. Not sensitivity or specificity of an identified test. [pmid: 5154768].
Suharjono Sunoto, Damajanti A, Darmawan S, et al. Small intestine biopsy in protein calorie malnutrition and celiac children. Paediatrica Indonesiana. 1971;11(5):7-15. Not sensitivity or specificity of an identified test. [pmid: 5158607].
Sujirachato K, Chiewsilp P, Tsuji K, et al. HLA class II polymorphism in Thai insulin-dependent diabetes mellitus. Tokai J Exp Clin Med. 1994;19(12):73-81. Not sensitivity or specificity of an identified test. [pmid: 7660388].
Sulkanen S, Halttunen T, Marttinen A, et al. Autoantibodies in celiac disease: importance of fibroblasts. Journal of Pediatric Gastroenterology and Nutrition. 1998;27(2):206-213. Not sensitivity or specificity of an identified test. [pmid: 9702655].
Sumi Yoshihiko, Inoue Nobutaka, Azumi Hiroshi, et al. Expression of tissue transglutaminase and elafin in human coronary artery: implication for plaque instability. Atherosclerosis. 2002;160(1):31-39. Not sensitivity or specificity of an identified test. [pmid: 11755920].
Summey Brett T, Graff Ronald D, Lai Thung, et al. Tissue transglutaminase localization and activity regulation in the extracellular matrix of articular cartilage. Journal of Orthopaedic Research - Official Publication of the Orthopaedic Research Society. 2002;20(1):76-82. Not sensitivity or specificity of an identified test. [pmid: 11853093].
Sumnik Z, Kolouskova S, Cinek O, et al. HLA-DQA1*05-DQB1*0201 positivity predisposes to coeliac disease in Czech diabetic children. Acta Paediatrica (Oslo, Norway - 1992). 2000;89(12):1426-1430. Improper control group. [pmid: 11195230].
Sundqvist T, Laurin P, Falth-Magnusson K, et al. Significantly increased levels of nitric oxide products in urine of children with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1998;27(2):196-198. Not sensitivity or specificity of an identified test. [pmid: 9702653].
Sung L A, Chien S, Fan Y S, et al. Human erythrocyte protein 4.2: isoform expression, differential splicing, and chromosomal assignment. Blood. 1992;79(10):2763-2770. Not sensitivity or specificity of an identified test. [pmid: 1350227].
Sunitha I, Meighen D L, Hartman D P, et al. Hepatocyte growth factor stimulates invasion across reconstituted basement membranes by a new human small intestinal cell line. Clinical & Experimental Metastasis. 1994;12(2):143-154. Not sensitivity or specificity of an identified test. [pmid: 8306528].
Suranyi Y, Freier S, Faber J, et al. Intestinal mast cells in different stages of celiac disease. Israel Journal of Medical Sciences. 1986;22(5):370-375. Unable to extract data. [pmid: 3744785].
Susi M, Holopainen P, Mustalahti K, et al. Candidate gene region 15q26 and genetic susceptibility to coeliac disease in Finnish families. Scandinavian Journal of Gastroenterology. 2001;36(4):372-374. Not sensitivity or specificity of an identified test. [pmid: 11336161].
Sutton G. Coeliac disease: Testing the New Zealand iceberg. New Zealand J Med Lab Sci. 2000;54(2):46-48. Not sensitivity or specificity of an identified test.
Suzuki M, Nikaido T, Ikegami M, et al. Renal adenoma. Clinicopathological and histochemical studies. Acta Pathologica Japonica. 1989;39(11):731-736. Not sensitivity or specificity of an identified test. [pmid: 2618660].
Svendsen M L, Daneels G, Geysen J, et al. Proliferation and differentiation of cultured human keratinocytes is modulated by 1,25(OH)2D3 and synthetic vitamin D3 analogues in a cell density-, calcium- and serum-dependent manner. Pharmacology & Toxicology. 1997;80(1):49-56. Not sensitivity or specificity of an identified test. [pmid: 9148283].
Svensson J, Carlsson A, Ericsson U-B, et al. Noonan's syndrome and autoimmune diseases. J Pediatr Endocrinol Metab. 2003;16(2):217-218. Not sensitivity or specificity of an identified test. [pmid: 12713260].
Sviridov D D, Izachik N A, Safonova I G, et al. Cholesterol synthesis in the small intestine of patients with malabsorption syndrome. Digestion. 1988;40(3):152-156. Not sensitivity or specificity of an identified test. [pmid: 3234621].
Sweeney E C, Masterson J B. Duodenal diaphragm with malabsorption. Ir Med J. 1974;67(19):510-512. Not sensitivity or specificity of an identified test. [pmid: 4430592].
Swinson C M, Levi A J. Is coeliac disease underdiagnosed?. British Medical Journal. 1980;281(6250):1258-1260. Not sensitivity or specificity of an identified test. [pmid: 7427659]. [pmcid: 1714677].
Swinson C M, Hall P J, Bedford P A, et al. HLA antigens in coeliac disease associated with malignancy. Gut. 1983;24(10):925-928. Not sensitivity or specificity of an identified test. [pmid: 6578173]. [pmcid: 1420156].
Swinson C M, Slavin G, Coles E C, et al. Coeliac disease and malignancy. Lancet. 1983;1(8316):111-115. Not sensitivity or specificity of an identified test. [pmid: 6129425].
Sylwestrowicz T, Kelly J K, Hwang W S, et al. Collagenous colitis and microscopic colitis: The watery diarrhea-colitis syndrome. American Journal of Gastroenterology. 1989;84(7):763-768. Not sensitivity or specificity of an identified test. [pmid: 2741886].
Szabo B, Jezernicky J, Kavai M. Immunological findings in primary malabsorption. Acta Paediatr Acad Sci Hung. 1982;23(3):337-342. Not sensitivity or specificity of an identified test. [pmid: 6758476].
Szabolcs M, Sipka S, Csorba S. In vitro cross-linking of gluten into high-molecular-weight polymers with transglutaminase. Acta Paediatrica Hungarica. 1987;28(34):215-227. Not sensitivity or specificity of an identified test. [pmid: 2900018].
Szaflarska-Szczepanik A, Czerwionka-Szaflarska M. The frequency of occurrence and clinical picture of celiac disease in the parents of children with the disease. Medical Science Monitor - International Medical Journal of Experimental and Clinical Research. 2001;7(5):971-976. Not sensitivity or specificity of an identified test. [pmid: 11535944].
Szaflarska-Szczepanik Anna. Assessment of correlation between the presence of antiendomysial antibodies and small intestine mucosal villous atrophy in the diagnostics of celiac disease. Medical Science Monitor - International Medical Journal of Experimental and Clinical Research. 2002;8(3):Cr185-Cr188. Not sensitivity or specificity of an identified test. [pmid: 11887033].
Szaflarska-Szczepanik A, Romanczuk W, Odrowaz-Sypniewska G, et al. Anti tissue transglutaminase antibodies (IgA(dagger)TG) for diagnosing of coeliac disease in children. Pediatr Wspolczesna. 2002;4(3):339-342. Unable to obtain full article.
Szegezdi E, Szondy Z, Nagy L, et al. Apoptosis-linked in vivo regulation of the tissue transglutaminase gene promoter. Cell Death Differ. 2000;7(12):1225-1233. Not sensitivity or specificity of an identified test. [pmid: 11175260].
Tabaqchali S, Hatzioannou J, Booth C C. Bile-salt deconjugation and steatorrhoea in patients with the stagnant-loop syndrome. Lancet. 1968;2(7558):12-16. Not sensitivity or specificity of an identified test. [pmid: 4172682].
Tabbaa M G, Axon A T R, Dixon M F. Enterocyte dimensions in patients with abnormal intestinal permeability. European Journal of Gastroenterology & Hepatology. 1994;6(7):607-610. Not sensitivity or specificity of an identified test.
Tabrez S, Roberts I M. Malabsorption and malnutrition. Primary Care. 2001;28(3):505-22. Not sensitivity or specificity of an identified test. [pmid: 11483441].
Tait B D, Harrison L C, Drummond B P, et al. HLA antigens and age at diagnosis of insulin-dependent diabetes mellitus. Hum Immunol. 1995;42(2):116-122. Not sensitivity or specificity of an identified test. [pmid: 7744614].
Takahashi H, Aoki N, Nakamura S, et al. Cornified cell envelope formation is distinct from apoptosis in epidermal keratinocytes. Journal of Dermatological Science. 2000;23(3):161-169. Not sensitivity or specificity of an identified test. [pmid: 10959041].
Takahashi H, Isobe T, Horibe S, et al. Tissue transglutaminase, coagulation factor XIII, and the pro-polypeptide of von Willebrand factor are all ligands for the integrins alpha 9beta 1 and alpha 4beta 1. Journal of Biological Chemistry. 2000;275(31):23589-23595. Not sensitivity or specificity of an identified test. [pmid: 10816592].
Takahashi M, Tezuka T. Hematoxylin stainable epidermal protein of the newborn rat. IV. The change of antigenicity in situ by transglutaminase as determined by an immunofluorescent study. J Dermatol. 1989;16(3):178-183. Not sensitivity or specificity of an identified test. [pmid: 2477425].
Takahashi M, Tezuka T, Katunuma N. Filaggrin linker segment peptide and cystatin alpha are parts of a complex of the cornified envelope of epidermis. Arch Biochem Biophys. 1996;329(1):123-126. Not sensitivity or specificity of an identified test. [pmid: 8619628].
Takahashi M, Tezuka T, Kakegawa H, et al. Linkage between phosphorylated cystatin alpha and filaggrin by epiderma) transglutaminase as a model of cornified envelope and inhibition of cathepsin L activity by cornified envelope and the conjugated cystatin alpha. Febs Lett. 1994;340(3):173-176. Not sensitivity or specificity of an identified test. [pmid: 7907550].
Takahashi N, Takahashi Y, Putnam F W. Primary structure of blood coagulation factor XIIIa (fibrinoligase, transglutaminase) from human placenta. Proceedings of the National Academy of Sciences of the United States of America. 1986;83(21):8019-8023. Not sensitivity or specificity of an identified test. [pmid: 2877456]. [pmcid: 386858].
Takaku K, Futamura M, Saitoh S, et al. Tissue-type transglutaminase is not a tumor-related marker. Journal of Biochemistry. 1995;118(6):1268-1270. Not sensitivity or specificity of an identified test. [pmid: 8720145].
Talal A H, Murray J A, Goeken J A, et al. Celiac disease in an adult population with insulin-dependent diabetes mellitus: use of endomysial antibody testing. American Journal of Gastroenterology. 1997;92(8):1280-1284. Not sensitivity or specificity of an identified test. [pmid: 9260789].
Talley N J, Kephart G M, McGovern T W, et al. Deposition of eosinophil granule major basic protein in eosinophilic gastroenteritis and celiac disease. Gastroenterology. 1992;103(1):137-145. Not sensitivity or specificity of an identified test. [pmid: 1612323].
Talme T, Schultzberg M, Sundqvist K G, et al. Somatostatin- and factor XIIIa-immunoreactive cells in psoriasis during clobetasol propionate and calciprotriol treatment. Acta Dermato-Venereologica. 1999;79(1):44-48. Not sensitivity or specificity of an identified test. [pmid: 10086858].
Tamada Y, Takama H, Kitamura T, et al. Expression of transglutaminase I in human anagen hair follicles. Acta Dermato-Venereologica. 1995;75(3):190-192. Not sensitivity or specificity of an identified test. [pmid: 7544520].
Taminiau J A. Celiac disease. Current Opinion in Pediatrics. 1996;8(5):483-486. Not sensitivity or specificity of an identified test. [pmid: 8946129].
Tanaka N, Fujioka A, Tajima S, et al. Levels of proelafin peptides in the sera of the patients with generalized pustular psoriasis and pustulosis palmoplantaris. Acta Dermato-Venereologica. 2000;80(2):102-105. Not sensitivity or specificity of an identified test. [pmid: 10877128].
Tanay Amir, Brickman Chaim M, Gas Svetlana, et al. TG or not TG: IgG-anti-tissue transglutaminase in systemic lupus erythematosus: new role for an old enzyme. Israel Medical Association Journal - Imaj. 2002;4(11 Suppl):878-879. Not sensitivity or specificity of an identified test.
Tandon N, Shtauvere-Brameus A, Hagopian W A et al. Prevalence of ICA-12 and other autoantibodies in north Indian patients with early-onset diabetes. Annals of the New York Academy of Sciences 2002;958214–217. Not sensitivity or specificity of an identified test
Taneja V, Malaviya A N, Mehra N K. Restriction fragment length polymorphisms in HLA-DR4-DQ3 haplotypes associated with rheumatoid arthritis. Indian J Med Res. (May). 1994;99:216-222. Not sensitivity or specificity of an identified test. [pmid: 7927579].
Taresa E, Kedei N, Thomazy V, et al. An involucrin-like protein in hepatocytes serves as a substrate for tissue transglutaminase during apoptosis. Journal of Biological Chemistry. 1992;267(36):25648-25651. Not sensitivity or specificity of an identified test. [pmid: 1361185].
Tarlo S M, Broder I, Prokipchuk E J. Association between celiac disease and lung disease. Chest. 1981;80(6):715-718. Not sensitivity or specificity of an identified test. [pmid: 6101248].
Tarmure Simina, Grigorescu Mircea, Cristea Anca, et al. Antiendomysial and antitissue transglutaminase antibodies in gluten-induced enteropathy. Romanian Journal of Gastroenterology. 2002;11(2):91-95. Improper control group. [pmid: 12145663].
Tate G, Ishizawa M. Structural similarity of the HLA-DQ region in DQ3 and DQ4 haplotypes and structural diversity of the HLA-DQ region in HLA-DR7 haplotypes. Microbiol Immunol. 1992;36(7):737-744. Not sensitivity or specificity of an identified test. [pmid: 1406376].
Taylor B, Sokol G. Cystic fibrosis and coeliac disease. Report of two cases. Arch Dis Child. 1973;48(9):692-696. Not sensitivity or specificity of an identified test. [pmid: 4733638].
Taylor C J. Predictive value of intraepithelial lymphocyte counts in childhood coeliac disease. Journal of Pediatric Gastroenterology and Nutrition. 1988;7(4):532-536. Unable to extract data. [pmid: 3397847].
Taylor C J, Smith S I, Morgan C H, et al. HLA and Mooren's ulceration. Br J Ophthalmol. 2000;84(1):72-75. Not sensitivity or specificity of an identified test. [pmid: 10611103]. [pmcid: 1723219].
Tedeschi A, Tuccari G, Magazzu G, et al. Immunohistochemical localization of lactoferrin in duodenojejunal mucosa from celiac children. Journal of Pediatric Gastroenterology and Nutrition. 1987;6(3):328-334. Not sensitivity or specificity of an identified test. [pmid: 3323437].
Teepe R G, Burger A, Ponec M. Immunohistochemical studies on regeneration in cultured epidermal autografts used to treat full-thickness burn wounds. Clinical and Experimental Dermatology. 1994;19(1):16-22. Not sensitivity or specificity of an identified test. [pmid: 8313632].
Teesalu K, Uibo O, Kalkkinen N, et al. Increased levels of IgA antibodies against desmin in children with coeliac disease. International Archives of Allergy and Immunology. 2001;126(2):157-166. Not sensitivity or specificity of an identified test. [pmid: 11729354].
ten Dam M, van de, Wal Y, et al. Anti-alpha-gliadin antibodies (AGA) in the serum of coeliac children and controls recognize an identical collection of linear epitopes of alpha-gliadin. Clinical and Experimental Immunology. 1998;114(2):189-195. Not sensitivity or specificity of an identified test. [pmid: 9822275]. [pmcid: 1905116].
Tepper R E, Simon D, Brandt L J, et al. Intestinal permeability in patients infected with the human immunodeficiency virus. American Journal of Gastroenterology. 1994;89(6):878-882. Not sensitivity or specificity of an identified test. [pmid: 8198098].
Teppo A M, Maury C P J. Antibodies to gliadin, gluten and reticulin glycoprotein in rheumatic diseases: Elevated levels in Sjogren's syndrome. Clinical and Experimental Immunology. 1984;57(1):73-78. Not sensitivity or specificity of an identified test. [pmid: 6378463]. [pmcid: 1536094].
ter Steege J, Buurman W, Arends J W, et al. Presence of inducible nitric oxide synthase, nitrotyrosine, CD68, and CD14 in the small intestine in celiac disease. Laboratory Investigation 1997;A Journal of Technical Methods and Pathology. 77(1):29-36. Not sensitivity or specificity of an identified test.
Tessier J L, Davies G A L. Giardiasis. Prim Care Update Ob Gyns. 1999;6(1):8-11. Not sensitivity or specificity of an identified test.
Thacher S M. Purification of keratinocyte transglutaminase and its expression during squamous differentiation. Journal of Investigative Dermatology. 1989;92(4):578-584. Not sensitivity or specificity of an identified test. [pmid: 2467949].
Thacher S M, Rice R H. Keratinocyte-specific transglutaminase of cultured human epidermal cells: relation to cross-linked envelope formation and terminal differentiation. Cell. 1985;40(3):685-695. Not sensitivity or specificity of an identified test. [pmid: 2578891].
Thacher S M, Rice R H. Monoclonal antibody to transglutaminase in the particulate fraction of human keratinocytes. Fed Proc 1984;43(6):No 2164Not sensitivity or specificity of an identified test
Thain M E, Hamilton J R, Ehrlich R M. Coexistence of diabetes mellitus and celiac disease. Journal of Pediatrics. 1974;85(4):527-529. Not sensitivity or specificity of an identified test. [pmid: 4443863].
Thapa B R. Celiac disease in India. Indian Journal of Pediatrics. 1999;66(1 Suppl):S16-S20. Not sensitivity or specificity of an identified test. [pmid: 11132463].
Thapa B R. Celiac disease in children: Recent concepts. Jk Science. 2001;3(1):3-12. Not sensitivity or specificity of an identified test.
Theintz G E, Nussle D, Cox J, et al. Prolactin and the gut: a controversy. Journal of Pediatric Gastroenterology and Nutrition. 1984;3(4):523-528. Not sensitivity or specificity of an identified test. [pmid: 6384457].
Theodor E, Gilon E. Protracted diarrhea of unknown etiology in Israeli soldiers. Israel Journal of Medical Sciences. 1975;11(5):458-464. Not sensitivity or specificity of an identified test. [pmid: 1158658].
Thomas A A, Martin S, Tate D G. An HLA-DQ2 specific cytotoxic alloantibody resulting from a failed renal transplant: A protocol for identification and verification. Eur J Immunogenet. 1992;19(6):460. Not sensitivity or specificity of an identified test.
Thomas A G, Phillips A D, Walker-Smith J A. The value of proximal small intestinal biopsy in the differential diagnosis of chronic diarrhoea. Archives of Disease in Childhood. 1992;67(6):741-743. Unable to extract data. [pmid: 1626996].
Thomas G L, Henley A, Rowland T C, et al. Enhanced apoptosis in transformed human lung fibroblasts after exposure to sodium butyrate. In Vitro Cellular & Developmental Biology Animal. 1996;32(8):505-513. Not sensitivity or specificity of an identified test. [pmid: 8889605].
Thomas L N, Wright A S, Lazier C B, et al. Prostatic involution in men taking finasteride is associated with elevated levels of insulin-like growth factor-binding proteins (IGFBPs)-2, -4, and -5. Prostate. 2000;42(3):203-210. Not sensitivity or specificity of an identified test. [pmid: 10639191].
Thomas P D, Forbes A, Green J, et al. Guidelines for the investigation of chronic diarrhoea, 2nd edition. Gut. 2003;52(Suppl 5):v1-v15. Not sensitivity or specificity of an identified test. [pmid: 12801941].
Thomazy V A, Davies P J A. Expression of tissue transglutaminase in the developing chicken limb is associated both with apoptosis and endochondral ossification. Cell Death Differ. 1999;6(2):146-154. Not sensitivity or specificity of an identified test. [pmid: 10200561].
Thomazy V, Fesus L. Differential expression of tissue transglutaminase in human cells. An immunohistochemical study. Cell and Tissue Research. 1989;255(1):215-224. Not sensitivity or specificity of an identified test. [pmid: 2567625].
Thomazy Vilmos A, Vega Francisco, Medeiros L, et al. Phenotypic modulation of the stromal reticular network in normal and neoplastic lymph nodes: tissue transglutaminase reveals coordinate regulation of multiple cell types. American Journal of Pathology. 2003;163(1):165-174. Not sensitivity or specificity of an identified test. [pmid: 12819021]. [pmcid: 1868169].
Thompson H. Pathology of coeliac disease. Current Topics in Pathology 1976;6349–75. Unable to extract data
Thompson H. The small intestine at autopsy. Clin Gastroenterol. 1974;3(1):171-181. Not sensitivity or specificity of an identified test. [pmid: 4600389].
Thomson A B, Keelan M, Thiesen A, et al. Small bowel review: diseases of the small intestine. Digestive Diseases and Sciences. 2001;46(12):2555-2566. Not sensitivity or specificity of an identified test. [pmid: 11768248].
Thomson G. HLA disease associations: models for the study of complex human genetic disorders. Crit Rev Clin Lab Sci. 1995;32(2):183-219. Not sensitivity or specificity of an identified test. [pmid: 7598790].
Thomson G. Investigation of the mode of inheritance of the HLA associated diseases by the method of antigen genotype frequencies among diseased individuals. Tissue Antigens. 1983;21(2):81-104. Not sensitivity or specificity of an identified test. [pmid: 6857627].
Thornquist H, Jacobsen G S, Dahl L B, et al. Coeliac disease and gluten-free diet: a following-up study of fifteen young adults. Annals of Nutrition & Metabolism. 1993;37(6):295-301. Not sensitivity or specificity of an identified test. [pmid: 8109888].
Thorsby E. Invited anniversary review: HLA associated diseases. Hum Immunol. 1997;53(1):1-11. Not sensitivity or specificity of an identified test. [pmid: 9361969].
Thorsby E, Lundin K E, Ronningen K S, et al. Molecular basis and functional importance of some disease-associated HLA polymorphisms. Tissue Antigens. 1989;34(1):39-49. Not sensitivity or specificity of an identified test. [pmid: 2617513].
Thurley C A, Kwan W C, Freeman H J, et al. T cell receptor gene expression and genotypes in celiac disease. Pathobiology - Journal of Immunopathology, Molecular and Cellular Biology. 1994;62(56):311-318. Not sensitivity or specificity of an identified test. [pmid: 7598800].
Tiberti C, Buzzetti R, Anastasi E, et al. Autoantibody negative new onset type 1 diabetic patients lacking high risk HLA alleles in a caucasian population: are these type 1b diabetes cases?. Diabetes/Metabolism Research and Reviews. 2000;16(1):8-14. Not sensitivity or specificity of an identified test. [pmid: 10707033].
Tighe M R, Ciclitira P J. The implications of recent advances in coeliac disease. Acta Paediatrica (Oslo, Norway - 1992). 1993;82(10):805-810. Not sensitivity or specificity of an identified test. [pmid: 8241634].
Tighe M R, Ciclitira P J. The gluten-host interaction. Bailliere's Clin Gastroenterol. 1995;9(2):211-230. Not sensitivity or specificity of an identified test. [pmid: 7549025].
Tighe M R, Hall M A, Ashkenazi A, et al. Celiac disease among Ashkenazi Jews from Israel A study of the HLA class II alleles and their associations with disease susceptibility. Human Immunology. 1993;38(4):270-276. Improper control group. [pmid: 8138422].
Tighe M R, Hall M A, Barbado M, et al. HLA class II alleles associated with celiac disease susceptibility in a southern European population. Tissue Antigens. 1992;40(2):90-97. Improper control group. [pmid: 1357780].
Tighe M R, Hall M A, Cardi E, et al. Associations between alleles of the major histocompatibility complex-encoded ABC transporter gene TAP2, HLA class II alleles, and celiac disease susceptibility. Human Immunology. 1994;39(1):9-16. Not sensitivity or specificity of an identified test. [pmid: 8181966].
Tighe R, Ciclitira P J. Molecular biology of coeliac disease. Archives of Disease in Childhood. 1995;73(3):189-191. Not sensitivity or specificity of an identified test. [pmid: 7492152].
Tighe R, Ciclitira P J. Celiac disease. Curr Opin Gastroenterol. 1995;11(2):112-115. Not sensitivity or specificity of an identified test.
Tikhonov YuV, Pimenov A M, Uzhevko S A et al. Ion-pair high-performance liquid chromatography of purine compounds in the small intestinal mucosa of children with coeliac disease. Journal of Chromatography 1990;520419–423. Not sensitivity or specificity of an identified test
Tiltman A J, Allard U. Female adnexal tumours of probable Wolffian origin: an immunohistochemical study comparing tumours, mesonephric remnants and paramesonephric derivatives. Histopathology. 2001;38(3):237-242. Not sensitivity or specificity of an identified test. [pmid: 11260305].
Timms B G, Lee C W, Aumuller G, et al. Instructive induction of prostate growth and differentiation by a defined urogenital sinus mesenchyme. Microsc Res Tech. 1995;30(4):319-332. Not sensitivity or specificity of an identified test. [pmid: 7606051].
Tiwana H, Walmsley R S, Wilson C, et al. Characterization of the humoral immune response to Klebsiella species in inflammatory bowel disease and ankylosing spondylitis. British Journal of Rheumatology. 1998;37(5):525-531. Not sensitivity or specificity of an identified test. [pmid: 9651080].
Tiwari J L, Betuel H, Gebuhrer L, et al. Genetic epidemiology of coeliac disease. Genetic Epidemiology. 1984;1(1):37-42. Not sensitivity or specificity of an identified test. [pmid: 6336186].
Toida M, Okumura Y, Swe Win K K, et al. Characterization of cells containing factor XIII subunit a in benign and malignant buccal lesions. Histochemical Journal. 1995;27(6):449-456. Not sensitivity or specificity of an identified test. [pmid: 7558894].
Tomkins A M, Drasar B S, James W P. Bacterial colonisation of jejunal mucosa in acute tropical sprue. Lancet. 1975;1(7898):59-62. Not sensitivity or specificity of an identified test. [pmid: 46020].
Tomkins A M, James W P, Walters J H, et al. Malabsorption in overland travellers to India. British Medical Journal. 1974;3(5927):380-384. Not sensitivity or specificity of an identified test. [pmid: 4853071]. [pmcid: 1613173].
Toner P G, Ferguson A. Intraepithelial cells in the human intestinal mucosa. Journal of Ultrastructure Research. 1971;34(3):329-344. Not sensitivity or specificity of an identified test. [pmid: 4323025].
Tonutti E, Visentini D, Bizzaro N, et al. The role of antitissue transglutaminase assay for the diagnosis and monitoring of coeliac disease: a French-Italian multicentre study. Journal of Clinical Pathology. 2003;56(5):389-393. Improper control group. [pmid: 12719462]. [pmcid: 1769943].
Torn C, Gupta M, Zake L N, et al. Heterozygosity for MICA5.0/MICA5.1 and HLA-DR3-DQ2/DR4-DQ8 are independent genetic risk factors for latent autoimmune diabetes in adults. Hum Immunol. 2003;64(9):902-909. Not sensitivity or specificity of an identified test. [pmid: 12941547].
Torrente F, Ashwood P, Day R, et al. Small intestinal enteropathy with epithelial IgG and complement deposition in children with regressive autism. Molecular Psychiatry. 2002;7(4):375-82, 334. Not sensitivity or specificity of an identified test. [pmid: 11986981].
Toscano V, Conti F G, Anastasi E, et al. Importance of gluten in the induction of endocrine autoantibodies and organ dysfunction in adolescent celiac patients. American Journal of Gastroenterology. 2000;95(7):1742-1748. Not sensitivity or specificity of an identified test. [pmid: 10925978].
Tosi R, Tanigaki N, Polanco I, et al. A radioimmunoassay typing study of non-DQw2-associated celiac disease. Clinical Immunology and Immunopathology. 1986;39(1):168-172. Not sensitivity or specificity of an identified test. [pmid: 3456292].
Tosi R, Vismara D, Tanigaki N, et al. Evidence that celiac disease is primarily associated with a DC locus allelic specificity. Clin Immunol Immunopathol. 1983;28(3):395-404. Not sensitivity or specificity of an identified test. [pmid: 6192959].
Townley R R. Diagnosis and treatment of coeliac disease in childhood. Medical Journal of Australia. 1971;1(13):696-698. Not sensitivity or specificity of an identified test. [pmid: 5553820].
Townley R R, Anderson C M. Coeliac disease. A review. Ergebnisse Der Inneren Medizin Und Kinderheilkunde 1967; 261–44. Not sensitivity or specificity of an identified test
Townley R R, Barnes G L. Intestinal biopsy in childhood. Archives of Disease in Childhood. 1973;48(6):480-482. Not sensitivity or specificity of an identified test. [pmid: 4712780].
Trabace S, Cappellacci S, Ciccarone P et al. Psoriatic arthritis: A clinical, radiological and genetic study of 58 Italian patients. Acta Derm-Venereol Suppl 1994;-(186):69–70. Not sensitivity or specificity of an identified test
Trabace S, Giunta A, Rosso M, et al. HLA-ABC and DR antigens in celiac disease. A study in a pediatric Italian population. Vox Sanguinis. 1984;46(2):102-106. Not sensitivity or specificity of an identified test. [pmid: 6422636].
Trejdosiewicz L K, Malizia G, Oakes J, et al. Expression of the common acute lymphoblastic leukaemia antigen (CALLA gp100) in the brush border of normal jejunum and jejunum of patients with coeliac disease. Journal of Clinical Pathology. 1985;38(9):1002-1006. Not sensitivity or specificity of an identified test. [pmid: 2931454]. [pmcid: 499349].
Trevisiol C, Not T, Berti I, et al. Screening for coeliac disease in healthy blood donors at two immuno-transfusion centres in north-east Italy. Italian Journal of Gastroenterology and Hepatology. 1999;31(7):584-586. Not sensitivity or specificity of an identified test. [pmid: 10604097].
Trevisiol C, Ventura A, Baldas V, et al. A reliable screening procedure for coeliac disease in clinical practice. Scandinavian Journal of Gastroenterology. 2002;37(6):679-684. Improper control group. [pmid: 12126246].
Trier J S. Diagnostic value of peroral biopsy of the proximal small intestine. New England Journal of Medicine. 1971;285(26):1470-1473. Not sensitivity or specificity of an identified test. [pmid: 4107817].
Trier J S. Organ-culture methods in the study of gastrointestinal-mucosal function and development. New England Journal of Medicine. 1976;295(3):150-155. Not sensitivity or specificity of an identified test. [pmid: 775333].
Trier J S. Medical progress: Celiac sprue. New Engl J Med. 1991;325(24):1709-1719. Not sensitivity or specificity of an identified test. [pmid: 1944472].
Trier J S, Browning T H. Epithelial-cell renewal in cultured duodenal biopsies in celiac sprue. New England Journal of Medicine. 1970;283(23):1245-1250. Not sensitivity or specificity of an identified test. [pmid: 5476480].
Trier J S, Moxey P C, Fordtran J S, et al. Ectopic gastric mucosa in celiac sprue. Gastroenterology. 1973;65(5):712-727. Not sensitivity or specificity of an identified test. [pmid: 4758969].
Trieshmann H W, Abraham G N, Santucci E A. The characterization of human anti IgG autoantibodies by liquid isoelectric focussing. J Immunol. 1975;114(1 I):176-181. Not sensitivity or specificity of an identified test. [pmid: 803526].
Trojani M, de Mascarel I, Coindre J M. Adenoid cystic carcinoma of the breast. Value of immunohistochemical study in diagnosis. Tumori. 1991;77(2):130-135. Not sensitivity or specificity of an identified test. [pmid: 1646511].
Troncone R. Towards new diagnostic criteria for coeliac disease. Ital J Pediat. 2002;28(4):245-248. Review article.
Troncone R, Ferguson A. Anti-gliadin antibodies. Journal of Pediatric Gastroenterology and Nutrition. 1991;12(2):150-158. Not sensitivity or specificity of an identified test. [pmid: 2051264].
Troncone R, Caputo N, Micillo M, et al. Immunologic and intestinal permeability tests as predictors of relapse during gluten challenge in childhood coeliac disease. Scandinavian Journal of Gastroenterology. 1994;29(2):144-147. Not sensitivity or specificity of an identified test. [pmid: 8171282].
Troncone R, Catassi C, Lambertini A, et al. Latent coeliac disease in Italy. Acta Paediatr Int J Paediatr. 1995;84(11):1252-1257. Improper control group.
Troncone R, Esposito C, Auricchio S. The role of tissue transglutaminase in the pathophysiology of coeliac disease. Minerva Biotecnol. 2002;14(2):177-180. Not sensitivity or specificity of an identified test.
Troncone R, Farris E, Donatiello A, et al. In vitro gliadin antibody production by peripheral blood mononuclear cells from patients with coeliac disease. Journal of Clinical & Laboratory Immunology. 1987;23(4):179-183. Not sensitivity or specificity of an identified test. [pmid: 3669062].
Troncone R, Gianfrani C, Mazzarella G, et al. Majority of gliadin-specific T-cell clones from celiac small intestinal mucosa produce interferon-gamma and interleukin-4. Digestive Diseases and Sciences. 1998;43(1):156-161. Not sensitivity or specificity of an identified test. [pmid: 9508518].
Troncone R, Greco L, Auricchio S. Gluten-sensitive enteropathy. Pediatric Clinics of North America. 1996;43(2):355-373. Not sensitivity or specificity of an identified test. [pmid: 8614605].
Troncone R, Greco L, Mayer M, et al. In siblings of celiac children, rectal gluten challenge reveals gluten sensitization not restricted to celiac HLA. Gastroenterology. 1996;111(2):318-324. Not sensitivity or specificity of an identified test. [pmid: 8690196].
Troncone R, Greco L, Mayer M et al. Latent and potential coeliac disease. Acta paediatrica (Oslo, Norway : 1992).Supplement 1996;41210–14. Not sensitivity or specificity of an identified test
Troncone R, Mayer M, Mugione P, et al. Cellobiose/mannitol sugar permeability test in children in relation to jejunal morphometry. Italian Journal of Gastroenterology. 1995;27(9):489-493. Not sensitivity or specificity of an identified test. [pmid: 8919317].
Troncone R, Mayer M, Spagnuolo F, et al. Endomysial antibodies as unreliable markers for slight dietary transgressions in adolescents with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1995;21(1):69-72. Not sensitivity or specificity of an identified test. [pmid: 8576818].
Troncone R, Mazzarella G, Leone N, et al. Gliadin activates mucosal cell mediated immunity in cultured rectal mucosa from coeliac patients and a subset of their siblings. Gut. 1998;43(4):484-489. Not sensitivity or specificity of an identified test. [pmid: 9824574]. [pmcid: 1727290].
Troncone R, Pignata C, Farris E. Suppressor cells and humoral immune response to gliadin in HLA-DR 3 or -DR 7 positive healthy subjects. Immunol Clin Sper. 1985;4(1):25-32. Not sensitivity or specificity of an identified test.
Troncone R, Pignata C, Farris E, et al. A solid-phase radioimmunoassay for IgG gliadin antibodies using 125I-labelled staphylococcal protein A. Journal of Immunological Methods. 1983;63(2):163-170. Serology <1990. [pmid: 6352817].
Troncone R, Starita A, Coletta S, et al. Antigliadin antibody, D-xylose, and cellobiose/mannitol permeability tests as indicators of mucosal damage in children with coeliac disease. Scandinavian Journal of Gastroenterology. 1992;27(8):703-706. Not sensitivity or specificity of an identified test. [pmid: 1439555].
Troncone R, Vitale M, Donatiello A, et al. A sandwich enzyme immunoassay for wheat gliadin. Journal of Immunological Methods. 1986;92(1):21-23. Not sensitivity or specificity of an identified test. [pmid: 3528299].
Troncone Riccardo, Franzese Adriana, Mazzarella Giuseppe, et al. Gluten sensitivity in a subset of children with insulin dependent diabetes mellitus. American Journal of Gastroenterology. 2003;98(3):590-595. Not sensitivity or specificity of an identified test. [pmid: 12650792].
Tsao S W, Chew E C, Yam H F, et al. Ultrastructural localization of a new surface membrane antigen (SQM1) related to squamous differentiation. In Vivo (Athens, Greece). 1989;3(6):367-374. Not sensitivity or specificity of an identified test. [pmid: 2519880].
Tshibassu M, Geboes K, Eggermont E, et al. Jejunal mucosa lymphoid cell subsets and the expression of major histocompatibility complex antigens in children. European Journal of Pediatrics. 1987;146(3):251-256. Not sensitivity or specificity of an identified test. [pmid: 3595644].
Tuccari G, Barresi G. Simultaneous demonstration of mucins and lysozyme in duodeno-jejunal biopsies of coeliac infants. Basic and Applied Histochemistry. 1984;28(2):177-182. Not sensitivity or specificity of an identified test. [pmid: 6477374].
Tucholski J, Kuret J, Johnson G V. Tau is modified by tissue transglutaminase in situ: possible functional and metabolic effects of polyamination. Journal of Neurochemistry. 1999;73(5):1871-1880. Not sensitivity or specificity of an identified test. [pmid: 10537045].
Tucholski J, Lesort M, Johnson G V. Tissue transglutaminase is essential for neurite outgrowth in human neuroblastoma SH-SY5Y cells. Neuroscience. 2001;102(2):481-491. Not sensitivity or specificity of an identified test. [pmid: 11166134].
Tucholski Janusz, Johnson Gail V. Tissue transglutaminase differentially modulates apoptosis in a stimuli-dependent manner. Journal of Neurochemistry. 2002;81(4):780-791. Not sensitivity or specificity of an identified test. [pmid: 12065637].
Tucholski Janusz, Johnson Gail V. Tissue transglutaminase directly regulates adenylyl cyclase resulting in enhanced cAMP-response element-binding protein (CREB) activation. Journal of Biological Chemistry. 2003;278(29):26838-26843. Not sensitivity or specificity of an identified test. [pmid: 12743114].
Tucker N T, Barghuthy F S, Prihoda T J, et al. Antigliadin antibodies detected by enzyme-linked immunosorbent assay as a marker of childhood celiac disease. Journal of Pediatrics. 1988;113(2):286-289. Serology <1990. [pmid: 3397791].
Tuckova L, Karska K, Walters J R, et al. Anti-gliadin antibodies in patients with celiac disease cross-react with enterocytes and human calreticulin. Clinical Immunology and Immunopathology. 1997;85(3):289-296. Not sensitivity or specificity of an identified test. [pmid: 9400629].
Tuckova L, Tlaskalova-Hogenova H, Farre M A, et al. Molecular mimicry as a possible cause of autoimmune reactions in celiac disease? Antibodies to gliadin cross-react with epitopes on enterocytes. Clinical Immunology and Immunopathology. 1995;74(2):170-176. Not sensitivity or specificity of an identified test. [pmid: 7828371].
Tumer L, Altuntas B, Hasanoglu A, et al. Pattern of human leukocyte antigens in Turkish children with celiac disease. Pediatrics International - Official Journal of the Japan Pediatric Society. 2000;42(6):678-681. Improper control group. [pmid: 11192527].
Tumer L, Hasanoglu A, Aybay C. Endomysium antibodies in the diagnosis of celiac disease in short-statured children with no gastrointestinal symptoms. Pediatrics International - Official Journal of the Japan Pediatric Society. 2001;43(1):71-73. Improper control group. [pmid: 11208004].
Tuncyurek M. Immunoglobulin-containing cells on intestinal wall in coeliac disease. Aegean Med J. 1979;8(1):31-37. Not sensitivity or specificity of an identified test.
Tuomilehto-Wolf E, Tuomilehto J. Is the high incidence of diabetes in young children diagnosed under the age of 4 years determined by genetic factors in Finland? The DIME Study Group. Diabete & Metabolisme. 1993;19(1 Pt 2):167-172. Not sensitivity or specificity of an identified test. [pmid: 8314421].
Turcu A, Leveque L, Bielefeld P, et al. Adult celiac disease and hemochromatosis. American Journal of Gastroenterology. 2000;95(12):3661-3662. Not sensitivity or specificity of an identified test. [pmid: 11151923].
Turner P M, Lorand L. Complexation of fibronectin with tissue transglutaminase. Biochemistry. 1989;28(2):628-635. Not sensitivity or specificity of an identified test. [pmid: 2565734].
Turowski G, Ke cedil. Soluble HLA class I antigens as a familial genetic background in coeliac disease. Cent-Eur J Immunol. 2001;26(1):28-30. Not sensitivity or specificity of an identified test.
Tursi A, Brandimarte G, Giorgetti G M. Sorbitol H2-breath test versus anti-endomysium antibodies for the diagnosis of subclinical/silent coeliac disease. Scandinavian Journal of Gastroenterology. 2001;36(11):1170-1172. Improper control group. [pmid: 11686216].
Tursi A, Brandimarte G, Giorgetti G M. Sorbitol H2-breath test versus anti-endomysium antibodies to assess histological recovery after gluten-free diet in coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(12):846-850. Not sensitivity or specificity of an identified test. [pmid: 12643292].
Tursi A, Brandimarte G, Giorgetti G M. Lack of Usefulness of Anti-Transglutaminase Antibodies in Assessing Histologic Recovery After Gluten-Free Diet in Celiac Disease. Journal of Clinical Gastroenterology. 2003;37(5):387-391. Not sensitivity or specificity of an identified test. [pmid: 14564185].
Tursi A, Brandimarte G, Giorgetti G M, et al. Effectiveness of the sorbitol HSUB2 breath test in detecting histological damage among relatives of coeliacs. Scandinavian Journal of Gastroenterology. 2003;38(7):727-731. Not sensitivity or specificity of an identified test. [pmid: 12889558].
Tursi A, Brandimarte G, Giorgetti G, et al. Low prevalence of antigliadin and anti-endomysium antibodies in subclinical/silent celiac disease. American Journal of Gastroenterology. 2001;96(5):1507-1510. Improper control group. [pmid: 11374690].
Tursi A, Giorgetti G, Brandimarte G, et al. Prevalence and clinical presentation of subclinical/silent celiac disease in adults: an analysis on a 12-year observation. Hepato-Gastroenterology. 2001;48(38):462-464. Not sensitivity or specificity of an identified test. [pmid: 11379333].
Tursi Antonio, Brandimarte Giovanni. The symptomatic and histologic response to a gluten-free diet in patients with borderline enteropathy. Journal of Clinical Gastroenterology. 2003;36(1):13-17. Not sensitivity or specificity of an identified test. [pmid: 12488700].
Tursi Antonio, Brandimarte Giovanni, Giorgetti Gian, et al. Prevalence of antitissue transglutaminase antibodies in different degrees of intestinal damage in celiac disease. Journal of Clinical Gastroenterology. 2003;36(3):219-221. Not sensitivity or specificity of an identified test. [pmid: 12590232].
Tursi Antonio, Brandimarte Giovanni, Giorgetti GianMarco. High prevalence of small intestinal bacterial overgrowth in celiac patients with persistence of gastrointestinal symptoms after gluten withdrawal. American Journal of Gastroenterology. 2003;98(4):839-843. Not sensitivity or specificity of an identified test. [pmid: 12738465].
Turton C W, Turner-Warwick M, Owens R, et al. Red cell folate levels, food antibodies and reticulin antibodies in farmer's lung--is there an association with coeliac disease?. British Journal of Diseases of the Chest. 1983;77(4):397-402. Not sensitivity or specificity of an identified test. [pmid: 6639866].
Tuysuz B, Dursun A, Kutlu T, et al. HLA-DQ alleles in patients with celiac disease in Turkey. Tissue Antigens. 2001;57(6):540-542. Unable to extract data. [pmid: 11556984].
Ueda E, Ohno S, Kuroki T, et al. The eta isoform of protein kinase C mediates transcriptional activation of the human transglutaminase 1 gene. Journal of Biological Chemistry. 1996;271(16):9790-9794. Not sensitivity or specificity of an identified test. [pmid: 8621660].
Ueki S, Takagi J, Saito Y. Dual functions of transglutaminase in novel cell adhesion. Journal of Cell Science. 1996;109(Pt):112727-2735. Not sensitivity or specificity of an identified test. [pmid: 8937990].
Ugurlu S, Bartley G B, Gibson L E. Necrobiotic xanthogranuloma: long-term outcome of ocular and systemic involvement. American Journal of Ophthalmology. 2000;129(5):651-657. Not sensitivity or specificity of an identified test. [pmid: 10844059].
Uhlig H H, Lichtenfeld J, Osman A A, et al. Evidence for existence of coeliac disease autoantigens apart from tissue transglutaminase. European Journal of Gastroenterology & Hepatology. 2000;12(9):1017-1020. Not sensitivity or specificity of an identified test. [pmid: 11007139].
Uhlig H, Osman A A, Tanev I D, et al. Role of tissue transglutaminase in gliadin binding to reticular extracellular matrix and relation to coeliac disease autoantibodies. Autoimmunity. 1998;28(4):185-195. Not sensitivity or specificity of an identified test. [pmid: 9892500].
Uibo O. Childhood celiac disease in Estonia: efficacy of the IgA-class antigliadin antibody test in the search for new cases. Journal of Pediatric Gastroenterology and Nutrition. 1994;18(1):53-55. Not sensitivity or specificity of an identified test. [pmid: 8126618].
Uibo O, Maaroos H I. Hospital screening of coeliac disease in Estonian children by anti-gliadin antibodies of IgA class. Acta Paediatrica (Oslo, Norway - 1992). 1993;82(3):233-234. Not sensitivity or specificity of an identified test. [pmid: 8495074].
Uibo O, Lambrechts A, Mascart-Lemone F. Human oesophagus: a convenient antigenic substrate for the determination of anti-endomysium antibodies in the serological diagnosis of coeliac disease. European Journal of Gastroenterology & Hepatology. 1995;7(1):37-40. Improper control group. [pmid: 7866808].
Uibo O, Metskula K, Kukk T, et al. Results of coeliac disease screening in Estonia in 1990-1994. Acta paediatrica (Oslo, Norway : 1992). Supplement. 1996:41239-41. Not sensitivity or specificity of an identified test.
Uibo O, Uibo R, Kleimola V, et al. Serum IgA anti-gliadin antibodies in an adult population sample. High prevalence without celiac disease. Digestive Diseases and Sciences. 1993;38(11):2034-2037. Not sensitivity or specificity of an identified test. [pmid: 8223078].
Uibo R, Sullivan E P, Uibo O, et al. Comparison of the prevalence of glutamic acid decarboxylase (GAD65) and gliadin antibodies (AGA) in a randomly selected adult estonian population. Hormone and Metabolic Research. Hormon- Und Stoffwechselforschung. Hormones Et Metabolisme. 2001;33(9):564-567. Not sensitivity or specificity of an identified test. [pmid: 11561218].
Uil J J, van Elburg R M, Janssens P M, et al. Sensitivity of a hyperosmolar or “low”-osmolar test solution for sugar absorption in recognizing small intestinal mucosal damage in coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2000;32(3):195-200. Not sensitivity or specificity of an identified test. [pmid: 10975768].
Uil J J, van Elburg R M, Mulder C J, et al. The value of the D-xylose test compared with the differential sugar absorption test in recognizing coeliac disease. Netherlands Journal of Medicine. 1996;49(2):68-72. Not sensitivity or specificity of an identified test. [pmid: 8824107].
Uil J J, van Elburg R M, van Overbeek F M, et al. Follow-up of treated coeliac patients: sugar absorption test and intestinal biopsies compared. European Journal of Gastroenterology & Hepatology. 1996;8(3):219-223. Not sensitivity or specificity of an identified test. [pmid: 8724020].
Ukabam S O, Cooper B T. Small intestinal permeability as an indicator of jejunal mucosal recovery in patients with celiac sprue on a gluten-free diet. Journal of Clinical Gastroenterology. 1985;7(3):232-236. Not sensitivity or specificity of an identified test. [pmid: 3926862].
Ukeda H, Ishii T, Shimizu Y, et al. Immunochemical approach to characterize post-translational modification of serum albumin using anti-glutaraldehyde-treated serum albumin antibodies. Bioscience, Biotechnology, and Biochemistry. 1997;61(2):341-346. Not sensitivity or specificity of an identified test. [pmid: 9058974].
Umar S, Malavasi F, Mehta K. Post-translational modification of CD38 protein into a high molecular weight form alters its catalytic properties. Journal of Biological Chemistry. 1996;271(27):15922-15927. Not sensitivity or specificity of an identified test. [pmid: 8663150].
Underhill J A, Donaldson P T, Doherty D G, et al. HLA DPB polymorphism in primary sclerosing cholangitis and primary biliary cirrhosis. Hepatology. 1995;21(4):959-962. Not sensitivity or specificity of an identified test. [pmid: 7705806].
Undlien D E, Friede T, Rammensee H-G, et al. HLA-encoded genetic predisposition in IDDM: DR4 subtypes may be associated with different degrees of protection. Diabetes. 1997;46(1):143-149. Not sensitivity or specificity of an identified test. [pmid: 8971095].
Undlien D E, Kockum I, Ronningen K S, et al. HLA associations in type 1 diabetes among patients not carrying high-risk DR3-DQ2 or DR4-DQ8 haplotypes. Tissue Antigens. 1999;54(6):543-551. Not sensitivity or specificity of an identified test. [pmid: 10674967].
Unsworth D J. Tissue transglutaminase: The major autoantigen in coeliac disease. Cpd Bull Immunol Allergy. 2000;1(2):51-53. Not sensitivity or specificity of an identified test.
Unsworth D J, Brown D L. Serological screening suggests that adult coeliac disease is underdiagnosed in the UK and increases the incidence by up to 12%. Gut. 1994;35(1):61-64. Not sensitivity or specificity of an identified test. [pmid: 8307451]. [pmcid: 1374633].
Unsworth D J, Dias J, Walker-Smith J A. Antigliadin and antireticulin antibodies in coeliac disease. Lancet. 1988;1(8587):705. Not sensitivity or specificity of an identified test. [pmid: 2895234].
Unsworth D J, Johnson G D, Haffenden G, et al. Binding of wheat gliadin in vitro to reticulum in normal and dermatitis herpetiformis skin. Journal of Investigative Dermatology. 1981;76(2):88-93. Not sensitivity or specificity of an identified test. [pmid: 6161972].
Unsworth D J, Kieffer M, Holborow E J, et al. IgA anti-gliadin antibodies in coeliac disease. Clinical and Experimental Immunology. 1981;46(2):286-293. Serology <1990. [pmid: 7039883]. [pmcid: 1536402].
Unsworth D J, Leonard J N, McMinn R M, et al. Anti-gliadin antibodies and small intestinal mucosal damage in dermatitis herpetiformis. British Journal of Dermatology. 1981;105(6):653-658. Not sensitivity or specificity of an identified test. [pmid: 7032573].
Unsworth D J, Lock R J, Harvey R F. Improving the diagnosis of coeliac disease in anaemic women. British Journal of Haematology. 2000;111(3):898-901. Not sensitivity or specificity of an identified test. [pmid: 11122153].
Unsworth D J, Manuel P D, Walker-Smith J A, et al. New immunofluorescent blood test for gluten sensitivity. Archives of Disease in Childhood. 1981;56(11):864-868. Not sensitivity or specificity of an identified test. [pmid: 7030226].
Unsworth J, Hutchins P, Mitchell J, et al. Flat small intestinal mucosa and autoantibodies against the gut epithelium. Journal of Pediatric Gastroenterology and Nutrition. 1982;1(4):503-513. Not sensitivity or specificity of an identified test. [pmid: 7186065].
Upchurch H F, Conway E, Patterson M K, et al. Localization of cellular transglutaminase on the extracellular matrix after wounding: characteristics of the matrix bound enzyme. Journal of Cellular Physiology. 1991;149(3):375-382. Not sensitivity or specificity of an identified test. [pmid: 1683874].
Upchurch H F, Conway E, Patterson M K, et al. Cellular transglutaminase has affinity for extracellular matrix. In Vitro Cellular & Developmental Biology - Journal of the Tissue Culture Association. 1987;23(11):795-800. Not sensitivity or specificity of an identified test. [pmid: 2890619].
Uray I P, Davies P J, Fesus L. Pharmacological separation of the expression of tissue transglutaminase and apoptosis after chemotherapeutic treatment of HepG2 cells. Molecular Pharmacology. 2001;59(6):1388-1394. Not sensitivity or specificity of an identified test. [pmid: 11353797].
Urbanski S J. Invited review/controversial issue: Can duodenal mucosa appear normal in gluten-sensitive enteropathy (celiac disease)?. Int J Surg Pathol. 1998;6(1):49-54. Review article.
Urso G, Longo A M, Bruno C M, et al. The role of the duodenal perendoscopic biopsy in the adult coeliac disease: LE ROLE DE LA BIOPSIE DUODENALE PERENDOSCOPIQUE DANS LE DIAGNOSTIC DE LA MALADIE COELIAQUE DE L'ADULTE. Acta Endosc. 1992;22(2):153-158. Not sensitivity or specificity of an identified test.
Urven L E, Abbott U K, Erickson C A. Distribution of extracellular matrix in the migratory pathway of avian primordial germ cells. Anat Rec. 1989;224(1):14-21. Not sensitivity or specificity of an identified test. [pmid: 2499221].
Urven L E, Erickson C A, Abbott U K, et al. Analysis of germ line development in the chick embryo using an antimouse EC cell antibody. Development. 1988;103(2):299-304. Not sensitivity or specificity of an identified test. [pmid: 2465117].
Usselmann B, Loft D E. An easy test for coeliac disease using human umbilical vein endothelial cells. European Journal of Gastroenterology & Hepatology. 1996;8(10):947-950. Review article. [pmid: 8930556].
Ussher R, Yeong M L, Stace N. Coeliac disease: incidence and prevalence in Wellington 1985-92. New Zealand Medical Journal. 1994;107(978):195-197. Not sensitivity or specificity of an identified test. [pmid: 8196863].
Usui T, Takagi J, Saito Y. Propolypeptide of von Willebrand factor serves as a substrate for factor XIIIa and is cross-linked to laminin. Journal of Biological Chemistry. 1993;268(17):12311-12316. Not sensitivity or specificity of an identified test. [pmid: 8099582].
Vader L, Willemijn de, Ru Arnoud, et al. Specificity of tissue transglutaminase explains cereal toxicity in celiac disease. Journal of Experimental Medicine. 2002;195(5):643-649. Not sensitivity or specificity of an identified test. [pmid: 11877487].
Vader Willemijn, Kooy Yvonne, van Veelen, et al. The gluten response in children with celiac disease is directed toward multiple gliadin and glutenin peptides. Gastroenterology. 2002;122(7):1729-1737. Not sensitivity or specificity of an identified test. [pmid: 12055577].
Vahedi Kouroche, Mascart Francoise, Mary Jean, et al. Reliability of antitransglutaminase antibodies as predictors of gluten-free diet compliance in adult celiac disease. American Journal of Gastroenterology. 2003;98(5):1079-1087. Not sensitivity or specificity of an identified test. [pmid: 12809831].
Vainio E. Immunoblotting analysis of antigliadin antibodies in the sera of patients with dermatitis herpetiformis and gluten-sensitive enteropathy. International Archives of Allergy and Applied Immunology. 1986;80(2):157-163. Not sensitivity or specificity of an identified test. [pmid: 3710610].
Vainio E, Varjonen E. Antibody response against wheat, rye, barley, oats and corn: comparison between gluten-sensitive patients and monoclonal antigliadin antibodies. International Archives of Allergy and Immunology. 1995;106(2):134-138. Not sensitivity or specificity of an identified test. [pmid: 7819741].
Vainio E, Collin P, Lehtonen O P. Avidity of antigliadin IgA and IgG antibodies in gluten-sensitive enteropathy and dermatitis herpetiformis. Clinical Immunology and Immunopathology. 1986;41(2):295-300. Not sensitivity or specificity of an identified test. [pmid: 3769223].
Vainio E, Kalimo K, Reunala T, et al. Circulating IgA- and IgG-class antigliadin antibodies in dermatitis herpetiformis detected by enzyme-linked immunosorbent assay. Archives of Dermatological Research. 1983;275(1):15-18. Not sensitivity or specificity of an identified test. [pmid: 6847240].
Vainio E, Kalimo K, Viander M, et al. Antigliadin antibodies and gluten-free diet in dermatitis herpetiformis. Acta Dermato-Venereologica. 1985;65(4):291-297. Not sensitivity or specificity of an identified test. [pmid: 2413682].
Vainio E, Kosnai I, Hallstrom O, et al. Antigliadin and antireticulin antibodies in children with dermatitis herpetiformis. Journal of Pediatric Gastroenterology and Nutrition. 1986;5(5):735-739. Not sensitivity or specificity of an identified test. [pmid: 3531458].
Valdimarsson T, Toss G, Lofman O, et al. Three years' follow-up of bone density in adult coeliac disease: Significance of secondary hyperparathyroidism. Scandinavian Journal of Gastroenterology. 2000;35(3):274-280. Not sensitivity or specificity of an identified test. [pmid: 10766321].
Valdimarsson T, Toss G, Ross I, et al. Bone mineral density in coeliac disease. Scandinavian Journal of Gastroenterology. 1994;29(5):457-461. Not sensitivity or specificity of an identified test. [pmid: 8036462].
Valdovinos M A, Camilleri M, Zimmerman B R. Chronic diarrhea in diabetes mellitus: mechanisms and an approach to diagnosis and treatment. Mayo Clinic Proceedings. 1993;68(7):691-702. Not sensitivity or specificity of an identified test. [pmid: 8350642].
Valentino R, Savastano S, Tommaselli A P, et al. Prevalence of coeliac disease in patients with thyroid autoimmunity. Hormone Research. 1999;51(3):124-127. Not sensitivity or specificity of an identified test. [pmid: 10461017].
Valentino Rossella, Savastano Silvia, Maglio Maria, et al. Markers of potential coeliac disease in patients with Hashimoto's thyroiditis. European Journal of Endocrinology / European Federation of Endocrine Societies. 2002;146(4):479-483. Not sensitivity or specificity of an identified test. [pmid: 11916614].
Valenzuela R, Shainoff J R, DiBello P M, et al. Immunoelectrophoretic and immunohistochemical characterizations of fibrinogen derivatives in atherosclerotic aortic intimas and vascular prosthesis pseudo-intimas. American Journal of Pathology. 1992;141(4):861-880. Not sensitivity or specificity of an identified test. [pmid: 1415480]. [pmcid: 1886632].
Valerio G, Maiuri L, Troncone R, et al. Severe clinical onset of diabetes and increased prevalence of other autoimmune diseases in children with coeliac disease diagnosed before diabetes mellitus. Diabetologia. 2002;45(12):1719-1722. Not sensitivity or specificity of an identified test. [pmid: 12488963].
Valeski J E, Kumar V, Beutner E H, et al. Immunology of celiac disease: tissue and species specificity of endomysial and reticulin antibodies. International Archives of Allergy and Applied Immunology. 1990;93(1):1-7. Not sensitivity or specificity of an identified test. [pmid: 2128295].
Valet G, Ormerod M G, Warnecke H H, et al. Sensitive three-parameter flow-cytometric detection of abnormal cells in human cervical cancers: a pilot study. Journal of Cancer Research and Clinical Oncology. 1981;102(2):177-184. Not sensitivity or specificity of an identified test. [pmid: 7338535].
Valletta E A, Mastella G. Adherence to gluten-free diet and serum antigliadin antibodies in celiac disease. Digestion. 1990;47(1):20-23. Not sensitivity or specificity of an identified test. [pmid: 2292344].
Valletta E A, Trevisiol D, Mastella G. IgA anti-gliadin antibodies in the monitoring of gluten challenge in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1990;10(2):169-173. Not sensitivity or specificity of an identified test. [pmid: 2303968].
Valnickova Z, Enghild J J. Human procarboxypeptidase U, or thrombin-activable fibrinolysis inhibitor, is a substrate for transglutaminases. Evidence for transglutaminase-catalyzed cross-linking to fibrin. Journal of Biological Chemistry. 1998;273(42):27220-27224. Not sensitivity or specificity of an identified test. [pmid: 9765243].
Van Beers E H, Einerhand A W C, Taminiau J A J M, et al. Pediatric duodenal biopsies: Mucosal morphology and glycohydrolase expression do not change along the duodenum. Journal of Pediatric Gastroenterology and Nutrition. 1998;26(2):186-193. Not sensitivity or specificity of an identified test. [pmid: 9669724].
van Belzen M J, Mulder C J, Pearson P L, et al. The tissue transglutaminase gene is not a primary factor predisposing to celiac disease. American Journal of Gastroenterology. 2001;96(12):3337-3340. Not sensitivity or specificity of an identified test. [pmid: 11774946].
Van Belzen, Martine J, Meijer Jos W R, et al. A major non-HLA locus in celiac disease maps to chromosome 19. Gastroenterology. 2003;125(4):1032-1041. Improper control group. [pmid: 14517787].
Van de, Kamer J H. Coeliac disease: A historical review. Ir Med J. 1974;67(15):405-406. Not sensitivity or specificity of an identified test. [pmid: 4606352].
van de, Staak W J, van Tongeren J H. Dermatitis herpetiformis and pathological changes of the mucous membrane of the small intestine. Dermatologica. 1970;140(4):231-241. Not sensitivity or specificity of an identified test. [pmid: 5425916].
van de, Wal Y, Kooy Y M, et al. Peptide binding characteristics of the coeliac disease-associated DQ(alpha1*0501, beta1*0201) molecule. Immunogenetics. 1996;44(4):246-253. Not sensitivity or specificity of an identified test. [pmid: 8753854].
van de, Wal Y, Kooy Y M, et al. Unique peptide binding characteristics of the disease-associated DQ(alpha 1*0501, beta 1*0201) vs the non-disease-associated DQ(alpha 1*0201, beta 1*0202) molecule. Immunogenetics. 1997;46(6):484-492. Not sensitivity or specificity of an identified test. [pmid: 9321428].
van de, Wal Y, Kooy Y M, et al. Small intestinal T cells of celiac disease patients recognize a natural pepsin fragment of gliadin. Proceedings of the National Academy of Sciences of the United States of America. 1998;95(17):10050-10054. Not sensitivity or specificity of an identified test. [pmid: 9707598]. [pmcid: 21459].
van de, Wal Y, Kooy Y M, et al. Glutenin is involved in the gluten-driven mucosal T cell response. European Journal of Immunology. 1999;29(10):3133-3139. Not sensitivity or specificity of an identified test. [pmid: 10540324].
van de, Wal Y, Kooy Y, et al. Selective deamidation by tissue transglutaminase strongly enhances gliadin-specific T cell reactivity. Journal of Immunology (Baltimore, Md.- 1950). 1998;161(4):1585-1588. Not sensitivity or specificity of an identified test. [pmid: 9712018].
van de, Wal Y, Kooy Y, et al. Cutting edge: Selective deamidation by tissue transglutaminase strongly enhances gliadin-specific T cell reactivity. J Immunol. 1998;161(4):1585-1588. Not sensitivity or specificity of an identified test. [pmid: 9712018].
van de, Wal Y, Kooy Y, et al. Coeliac disease: it takes three to tango!. Gut. 2000;46(5):734-737. Review article. [pmid: 10764722]. [pmcid: 1727918].
van den, Bosch H C, Tham R T, et al. Celiac disease: small-bowel enteroclysis findings in adult patients treated with a gluten-free diet. Radiology. 1996;201(3):803-808. Not sensitivity or specificity of an identified test. [pmid: 8939235].
Van Der, Burg S H, Ressing M E, et al. Natural T-helper immunity against human papillomavirus type 16 (HPV16) E7-derived peptide epitopes in patients with HPV16-positive cervical lesions: Identification of 3 human leukocyte antigen class II-restricted epitopes. Int J Cancer. 2001;91(5):612-618. Not sensitivity or specificity of an identified test. [pmid: 11267969].
van der, Zee J M, Heurkens A H, et al. Characterization of anti-endothelial antibodies in patients with rheumatoid arthritis complicated by vasculitis. Clinical and Experimental Rheumatology. 1991;9(6):589-594. Not sensitivity or specificity of an identified test. [pmid: 1764841].
van der, Zee J M, Miltenburg A M, et al. Antiendothelial cell antibodies in systemic lupus erythematosus: enhanced antibody binding to interleukin-1-stimulated endothelium. International Archives of Allergy and Immunology. 1994;104(2):131-136. Not sensitivity or specificity of an identified test. [pmid: 8199456].
van Elburg R M, Uil J J, Mulder C J, et al. Intestinal permeability in patients with coeliac disease and relatives of patients with coeliac disease. Gut. 1993;34(3):354-357. Not sensitivity or specificity of an identified test. [pmid: 8472983]. [pmcid: 1374141].
van Lith M, van Ham M, Neefjes J. Novel polymorphisms in HLA-DOA and HLA-DOB in B-cell malignancies. Immunogenetics. 2002;54(8):591-595. Not sensitivity or specificity of an identified test. [pmid: 12439622].
Van Mook W N K A, Bourass-Bremer I H D N, Bos L P, et al. The outcome of esophagogastroduodenoscopy (EGD) in asymptomatic outpatients with iron deficiency anemia after a negative colonoscopy. Eur J Intern Med. 2001;12(2):122-126. Not sensitivity or specificity of an identified test. [pmid: 11297915].
van Rood J J. HLA as regulator. Annals of the Rheumatic Diseases. 1984;43(5):665-672. Not sensitivity or specificity of an identified test. [pmid: 6208855]. [pmcid: 1001506].
van Rood J J. The impact of the major histocompatibility complex on graft survival and disease susceptibility. Genetics. 1975;79(Suppl):277-291. Not sensitivity or specificity of an identified test. [pmid: 125216].
van Spreeuwel J P, Meijer C J, Rosekrans P C, et al. Immunoglobulin-containing cells in gastrointestinal pathology--diagnostic applications. Pathology Annual. 1986;21(Pt 1):295-310. Not sensitivity or specificity of an identified test. [pmid: 3510417].
Van Stirum J, Baerlocher K, Fanconi A. The incidence of coeliac disease in children in Switzerland. Helv Paediatr Acta. 1982;37(5):421-430. Not sensitivity or specificity of an identified test. [pmid: 7161114].
van Straaten E A, Koster-Kamphuis L, Bovee-Oudenhoven I M, et al. Increased urinary nitric oxide oxidation products in children with active coeliac disease. Acta Paediatrica (Oslo, Norway - 1992). 1999;88(5):528-531. Not sensitivity or specificity of an identified test. [pmid: 10426175].
van der, Sluijs V, Vermes I. IgG autoantibodies against tissue transglutaminase in relation to antinuclear antibodies. Clinical Chemistry. 2001;47(5):952-954. Not sensitivity or specificity of an identified test. [pmid: 11325907].
Vancikova Z, Chlumecky V, Sokol D, et al. The serologic screening for celiac disease in the general population (blood donors) and in some high-risk groups of adults (patients with autoimmune diseases, osteoporosis and infertility) in the Czech republic. Folia Microbiologica. 2002;47(6):753-758. Not sensitivity or specificity of an identified test. [pmid: 12630332].
Vancikova Z, Kocna P, Tuckova L, et al. Characterization of human, mouse and rabbit anti-gliadin antibodies by ELISA and western blotting. Folia Microbiologica. 1995;40(6):659-664. Not sensitivity or specificity of an identified test. [pmid: 8768258].
Vandermeeren M, Daneels G, Bergers M, et al. Development and application of monoclonal antibodies against SKALP/elafin and other trappin family members. Arch Dermatol Res. 2001;293(7):343-349. Not sensitivity or specificity of an identified test. [pmid: 11550807].
Vardaman C, Albores-Saavedra J. Clear cell carcinomas of the gallbladder and extrahepatic bile ducts. American Journal of Surgical Pathology. 1995;19(1):91-99. Not sensitivity or specificity of an identified test. [pmid: 7802141].
Variend S, Phillips A D, Walker-Smith J A. The small intestinal mucosal biopsy in childhood. Perspectives in Pediatric Pathology. 1984;8(1):57-78. Not sensitivity or specificity of an identified test. [pmid: 6422441].
Variend S, Placzek M, Raafat F, et al. Small intestinal mucosal fat in childhood enteropathies. Journal of Clinical Pathology. 1984;37(4):373-377. Not sensitivity or specificity of an identified test. [pmid: 6707223]. [pmcid: 498736].
Varjonen E, Kalimo K, Savolainen J, et al. IgA and IgG binding components of wheat, rye, barley and oats recognized by immunoblotting analysis with sera from adult atopic dermatitis patients. International Archives of Allergy and Immunology. 1996;111(1):55-63. Not sensitivity or specificity of an identified test. [pmid: 8753845].
Varjonen E, Vainio E, Kalimo K. Antigliadin IgE--indicator of wheat allergy in atopic dermatitis. Allergy. 2000;55(4):386-391. Not sensitivity or specificity of an identified test. [pmid: 10782525].
Varkonyi A, Boda M, Endreffy E et al. Coeliac disease: always something to discover. Scandinavian Journal of Gastroenterology.Supplement 1998;228122–129. Not sensitivity or specificity of an identified test
Varljen J, Persic M, Milin C, et al. Intestinal alkaline phosphatase and disaccharidases in children with gluten enteropathy. Acta Pharm. 1994;44(4):319-324. Not sensitivity or specificity of an identified test.
Vartdal F, Johansen B H, Friede T, et al. The peptide binding motif of the disease associated HLA-DQ (alpha 1* 0501, beta 1* 0201) molecule. European Journal of Immunology. 1996;26(11):2764-2772. Not sensitivity or specificity of an identified test. [pmid: 8921967].
Vasmant D, Feldmann G, Fontaine J L. Ultrastructural localization of concanavalin a surface receptors on brush-border enterocytes in normal children and during coeliac disease. Pediatric Research. 1982;16(6):441-445. Not sensitivity or specificity of an identified test. [pmid: 7099760].
Vatay Agnes, Rajczy Katalin, Pozsonyi Eva, et al. Differences in the genetic background of latent autoimmune diabetes in adults (LADA) and type 1 diabetes mellitus. Immunology Letters. 2002;84(2):109-115. Not sensitivity or specificity of an identified test. [pmid: 12270547].
Vazquez H, Cabanne A, Sugai E, et al. Serological markers identify histologically latent coeliac disease among first-degree relatives. European Journal of Gastroenterology & Hepatology. 1996;8(1):15-21. Not sensitivity or specificity of an identified test. [pmid: 8900904].
Vazquez H, Sugai E, Pedreira S, et al. Screening for asymptomatic celiac sprue in families. Journal of Clinical Gastroenterology. 1995;21(2):130-133. Improper control group. [pmid: 8583078].
Vecchi M, Folli C, Donato M F, et al. High rate of positive anti-tissue transglutaminase antibodies in chronic liver disease. Role of liver decompensation and of the antigen source. Scandinavian Journal of Gastroenterology. 2003;38(1):50-54. Not sensitivity or specificity of an identified test. [pmid: 12608464].
Vecchi M, Torgano G, De Franchis R, et al. Evidence of altered structural and secretory glycoconjugates in the jejunal mucosa of patients with gluten sensitive enteropathy and subtotal villous atrophy. Gut. 1989;30(6):804-810. Not sensitivity or specificity of an identified test. [pmid: 2753405]. [pmcid: 1434154].
Veitch A M, Kelly P, Zulu I S, et al. Tropical enteropathy: a T-cell-mediated crypt hyperplastic enteropathy. European Journal of Gastroenterology & Hepatology. 2001;13(10):1175-1181. Not sensitivity or specificity of an identified test. [pmid: 11711773].
Velasco P T, Karush F, Lorand L. Transamidating activities of factor XIIIa and of transglutaminases, measured by an ELISA procedure. Biochemical and Biophysical Research Communications. 1988;152(2):505-511. Not sensitivity or specificity of an identified test. [pmid: 2896499].
Velluzzi F, Caradonna A, Boy M F, et al. Thyroid and celiac disease: clinical, serological, and echographic study. American Journal of Gastroenterology. 1998;93(6):976-979. Not sensitivity or specificity of an identified test. [pmid: 9647032].
Veloso F T, Saleiro J V. Small-bowel changes in recurrent ulceration of the mouth. Hepato-Gastroenterology. 1987;34(1):36-37. Not sensitivity or specificity of an identified test. [pmid: 3570141].
Ventura A, Martelossi S. The old and new coeliac disease. Eur J Pediatr Dermatol. 1995;5(2):87-94. Not sensitivity or specificity of an identified test.
Ventura A, Facchini S, Amantidu C, et al. Searching for celiac disease in pediatric general practice. Clin Pediatr. 2001;40(10):575-577. Not sensitivity or specificity of an identified test.
Venturini I, Cosenza R, Miglioli L, et al. Adult celiac disease and primary sclerosing cholangitis: two case reports. Hepato-Gastroenterology. 1998;45(24):2344-2347. Not sensitivity or specificity of an identified test. [pmid: 9951920].
Verbeke S, Gotteland M, Fernandez M, et al. Basement membrane and connective tissue proteins in intestinal mucosa of patients with coeliac disease. Journal of Clinical Pathology. 2002;55(6):440-445. Not sensitivity or specificity of an identified test. [pmid: 12037027]. [pmcid: 1769663].
Verderio E A M, Telci D, Okoye A, et al. A Novel RGD-independent Cell Adhesion Pathway Mediated by Fibronectin-bound Tissue Transglutaminase Rescues Cells from Anoikis. J Biol Chem. 2003;278(43):42604-42614. Not sensitivity or specificity of an identified test. [pmid: 12732629].
Verderio E, Coombes A, Jones R A, et al. Role of the cross-linking enzyme tissue transglutaminase in the biological recognition of synthetic biodegradable polymers. Journal of Biomedical Materials Research. 2001;54(2):294-304. Not sensitivity or specificity of an identified test. [pmid: 11093190].
Verderio E, Nicholas B, Gross S, et al. Regulated expression of tissue transglutaminase in Swiss 3T3 fibroblasts: effects on the processing of fibronectin, cell attachment, and cell death. Experimental Cell Research. 1998;239(1):119-138. Not sensitivity or specificity of an identified test. [pmid: 9511731].
Veres G, Helin T, Arato A, et al. Increased expression of intercellular adhesion molecule-1 and mucosal adhesion molecule alpha4beta7 integrin in small intestinal mucosa of adult patients with food allergy. Clinical Immunology (Orlando, Fla.). 2001;99(3):353-359. Not sensitivity or specificity of an identified test. [pmid: 11358431].
Verge C F, Gianani R, Kawasaki E, et al. Prediction of type I diabetes in first-degree relatives using a combination of insulin, GAD, and ICA512bdc/IA-2 autoantibodies. Diabetes. 1996;45(3 SUPPL.):926-933. Not sensitivity or specificity of an identified test. [pmid: 8666144].
Verge C F, Howard N J, Rowley M J, et al. Anti-glutamate decarboxylase and other antibodies at the onset of childhood IDDM: a population-based study. Diabetologia. 1994;37(11):1113-1120. Not sensitivity or specificity of an identified test. [pmid: 7867883].
Verkarre V, Asnafi V, Lecomte T, et al. Refractory coeliac sprue is a diffuse gastrointestinal disease. Gut. 2003;52(2):205-211. Not sensitivity or specificity of an identified test. [pmid: 12524401]. [pmcid: 1774980].
Verkasalo M. HLA and lymphocyte receptors for gliadin peptides. Klinische Padiatrie. 1985;197(4):334-335. Not sensitivity or specificity of an identified test. [pmid: 4046493].
Verkasalo M A. Adherence of gliadin fractions to lymphocytes in coeliac disease. Lancet. 1982;1(8286):1384-1386. Not sensitivity or specificity of an identified test. [pmid: 6123679].
Verkasalo M A, Arato A, Savilahti E, et al. Effect of diet and age on jejunal and circulating lymphocyte subsets in children with coeliac disease: persistence of CD4-8-intraepithelial T cells through treatment. Gut. 1990;31(4):422-425. Not sensitivity or specificity of an identified test. [pmid: 2338267]. [pmcid: 1378416].
Verkasalo M, Kuitunen P, Leisti S, et al. Growth failure from symptomless celiac disease. A study of 14 patients. Helvetica Paediatrica Acta. 1978;33(6):489-495. Not sensitivity or specificity of an identified test. [pmid: 216652].
Verkasalo M, Kuitunen P, Tiilikainen A, et al. HLA antigens in intestinal cow's milk allergy. Acta Paediatrica Scandinavica. 1983;72(1):19-22. Not sensitivity or specificity of an identified test. [pmid: 6574688].
Verkasalo M, Tiilikainen A, Kuitunen P, et al. HLA antigens and atopy in children with coeliac disease. Gut. 1983;24(4):306-310. Not sensitivity or specificity of an identified test. [pmid: 6601040]. [pmcid: 1419972].
Vermeer B J, Lindeman J, Harst-Oostveen C J, et al. The immunoglobulin-bearing cells in the lamina propria and the clinical response to a gluten-free diet in dermatitis herpetiformis. Archives for Dermatological Research. Archiv Fur Dermatologische Forschung. 1977;258(3):223-230. Not sensitivity or specificity of an identified test.
Vermelin L, Lecolle S, Septier D, et al. Apoptosis in human and rat dental pulp. European Journal of Oral Sciences. 1996;104(56):547-553. Not sensitivity or specificity of an identified test. [pmid: 9021324].
Verreck F A W, Van De, Poel A, et al. Identification of an HLA-DQ2 peptide binding motif and HLA-DPw3-hound self-peptide by pool sequencing. Eur J Immunol. 1994;24(2):375-379. Not sensitivity or specificity of an identified test. [pmid: 8299686].
Vesy C J, Greenson J K, Papp A C, et al. Evaluation of celiac disease biopsies for adenovirus 12 DNA using a multiplex polymerase chain reaction. Modern Pathology - an Official Journal of the United States and Canadian Academy of Pathology, Inc. 1993;6(1):61-64. Not sensitivity or specificity of an identified test. [pmid: 8381233].
Vezza R, Habib A, FitzGerald G A. Differential signaling by the thromboxane receptor isoforms via the novel GTP-binding protein, Gh. Journal of Biological Chemistry. 1999;274(18):12774-12779. Not sensitivity or specificity of an identified test. [pmid: 10212262].
Victora C G, Barros F C, Horta B L, et al. Short-term benefits of catch-up growth for small-for-gestational-age infants. International Journal of Epidemiology. 2001;30(6):1325-1330. Not sensitivity or specificity of an identified test. [pmid: 11821340].
Vielh P, Validire P, Kheirallah S, et al. Paget's disease of the nipple without clinically and radiologically detectable breast tumor. Histochemical and immunohistochemical study of 44 cases. Pathology, Research and Practice. 1993;189(2):150-155. Not sensitivity or specificity of an identified test. [pmid: 8391688].
Viken H D, Paulsen G, Drover S, et al. Influence on antibody recognition of amino acid substitutions in the cleft of HLA-DQ2 molecules: Suggestive evidence of peptide-dependent epitopes. Hum Immunol. 1995;44(2):63-69. Not sensitivity or specificity of an identified test. [pmid: 8847230].
Viken H D, Paulsen G, Sollid L M, et al. Characterization of an HLA-DQ2-specific monoclonal antibody. Influence of amino acid substitutions in DQ beta 1*0202. Human Immunology. 1995;42(4):319-327. Not sensitivity or specificity of an identified test. [pmid: 8847230].
Viken H D, Thoresen A B, Thorsby E, et al. The cytotoxic HLA-DQ3 reactive human hybridoma antibody 4166 that may distinguish DQ7+8 from DQ9. Hum Immunol. 1995;42(4):281-288. Not sensitivity or specificity of an identified test. [pmid: 7558937].
Viken H D, Thorsby E, Gaudernack G. Characterization and epitope mapping of four HLA class II reactive mouse monoclonal antibodies using transfected L cells and human cells transfected with mutants of DQB1(*)0302. Tissue Antigens. 1995;45(4):250-257. Not sensitivity or specificity of an identified test. [pmid: 7638861].
Vila T J, Medina Z M, Cusi S V, et al. Computerized morphometric analysis of jejunal biopsy: A simple and useful method for the routine diagnosis of coeliac disease. J Clin Nutr Gastroenterol. 1989;4(4):173-182. Unable to obtain full article.
Villanacci V, Facchetti F, Pillan N, et al. Expression of cell adhesion molecules in jejunum biopsies of children with coeliac disease. Italian Journal of Gastroenterology. 1993;25(3):109-116. Not sensitivity or specificity of an identified test. [pmid: 8507887].
Visakorpi J K. The diagnosis of coeliac disease. Ann Nestle. 1993;51(2):43-49. Not sensitivity or specificity of an identified test.
Visakorpi J K, Kuitunen P, Savilahti E. Frequency and nature of relapses in children suffering from the malabsorption syndrome with gluten intolerance. Acta Paediatrica Scandinavica. 1970;59(5):481-486. Not sensitivity or specificity of an identified test. [pmid: 5455517].
Viskari H, Paronen J, Keskinen P, et al. Humoral beta-cell autoimmunity is rare in patients with the congenital rubella syndrome. Clinical and Experimental Immunology. 2003;133(3):378-383. Not sensitivity or specificity of an identified test. [pmid: 12930364]. [pmcid: 1808787].
Visser H, Vos K, Zanelli E, et al. Sarcoid arthritis: Clinical characteristics, diagnostic aspects, and risk factors. Ann Rheum Dis. 2002;61(6):499-504. Not sensitivity or specificity of an identified test. [pmid: 12006321]. [pmcid: 1754119].
Vitoria J C. Expert's comments. J Postgrad Med. 2003;49(1):24. Not sensitivity or specificity of an identified test.
Vitoria J C, Arrieta A, Arranz C, et al. Antibodies to gliadin, endomysium, and tissue transglutaminase for the diagnosis of celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1999;29(5):571-574. Improper control group. [pmid: 10554125].
Vitoria J C, Arrieta A, Astigarraga I, et al. Use of serological markers as a screening test in family members of patients with celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1994;19(3):304-309. Not sensitivity or specificity of an identified test. [pmid: 7815262].
Vitoria J C, Castano L, Rica I, et al. Association of insulin-dependent diabetes mellitus and celiac disease: a study based on serologic markers. Journal of Pediatric Gastroenterology and Nutrition. 1998;27(1):47-52. Not sensitivity or specificity of an identified test. [pmid: 9669725].
Vivas Santiago, Ruiz de, Morales Jose M, et al. Human recombinant anti-transglutaminase antibody testing is useful in the diagnosis of silent coeliac disease in a selected group of at-risk patients. European Journal of Gastroenterology & Hepatology. 2003;15(5):479-483. Not sensitivity or specificity of an identified test. [pmid: 12702903].
Vjero Katerina, Martucci Susi, Alvisi Costanza, et al. Defining a proper setting for endoscopy in coeliac disease. European Journal of Gastroenterology & Hepatology. 2003;15(6):675-678. Not sensitivity or specificity of an identified test. [pmid: 12840680].
Vogelsang H, Hanel S, Steiner B, et al. Diagnostic duodenal bulb biopsy in celiac disease. Endoscopy. 2001;33(4):336-340. Not sensitivity or specificity of an identified test. [pmid: 11315895].
Vogelsang H, Oberhuber G, Wyatt J. Lymphocytic gastritis and gastric permeability in patients with celiac disease. Gastroenterology. 1996;111(1):73-77. Not sensitivity or specificity of an identified test. [pmid: 8698227].
Vogelsang H, Schwarzenhofer M, Oberhuber G. Changes in gastrointestinal permeability in celiac disease. Digestive Diseases (Basel, Switzerland). 1998;16(6):333-336. Not sensitivity or specificity of an identified test. [pmid: 10207219].
Vogelsang H, Schwarzenhofer M, Granditsch G, et al. In vitro production of endomysial antibodies in cultured duodenal mucosa from patients with celiac disease. American Journal of Gastroenterology. 1999;94(4):1057-1061. Not sensitivity or specificity of an identified test. [pmid: 10201483].
Vogelsang H, Schwarzenhofer M, Steiner B, et al. In vivo and in vitro permeability in coeliac disease. Alimentary Pharmacology & Therapeutics. 2001;15(9):1417-1425. Not sensitivity or specificity of an identified test. [pmid: 11552914].
Vogelsang H, Wyatt J, Penner E, et al. Screening for celiac disease in first-degree relatives of patients with celiac disease by lactulose/mannitol test. American Journal of Gastroenterology. 1995;90(10):1838-1842. Not sensitivity or specificity of an identified test. [pmid: 7572905].
Vogelsang Harald, Panzer Simon, Mayr Wolfgang R, et al. Distribution of HLA class I alleles differs in celiac disease patients according to age of onset. Digestive Diseases and Sciences. 2003;48(3):611-614. Not sensitivity or specificity of an identified test. [pmid: 12757179].
Vollberg T M, George M D, Nervi C, et al. Regulation of type I and type II transglutaminase in normal human bronchial epithelial and lung carcinoma cells. American Journal of Respiratory Cell and Molecular Biology. 1992;7(1):10-18. Not sensitivity or specificity of an identified test. [pmid: 1352692].
Volokhina E B, Hulshof R, Haanen C, et al. Tissue transglutaminase mRNA expression in apoptotic cell death. Apoptosis. 2003;8(6):673-679. Not sensitivity or specificity of an identified test. [pmid: 14739613].
Volta U, Bellentani S, Bianchi F B, et al. High prevalence of celiac disease in Italian general population. Digestive Diseases and Sciences. 2001;46(7):1500-1505. Not sensitivity or specificity of an identified test. [pmid: 11478502].
Volta U, Bonazzi C, Baldoni A M, et al. Clinical presentation of adult coeliac disease. Ann Med Interne (Paris). 1988;139(2):123-124. Not sensitivity or specificity of an identified test. [pmid: 3395054].
Volta U, Bonazzi C, Lazzari R, et al. Immunoglobulin A antigliadin antibodies in jejunal juice: markers of severe intestinal damage in coeliac children. Digestion. 1988;39(1):35-39. Not sensitivity or specificity of an identified test. [pmid: 3396771].
Volta U, Bonazzi C, Pisi E, et al. Antigliadin and antireticulin antibodies in coeliac disease and at onset of diabetes in children. Lancet. 1987;2(8566):1034-1035. Not sensitivity or specificity of an identified test. [pmid: 2889951].
Volta U, Cassani F, De Franchis R, et al. Antibodies to gliadin in adult coeliac disease and dermatitis herpetiformis. Digestion. 1984;30(4):263-270. Serology <1990. [pmid: 6391982].
Volta U, Corazza G R, Frisoni M, et al. IgA antigliadin antibodies and persistence of jejunal lesions in adult coeliac disease. Digestion. 1990;47(2):111-114. Not sensitivity or specificity of an identified test. [pmid: 2292352].
Volta U, De Franceschi L, Lari F, et al. Coeliac disease hidden by cryptogenic hypertransaminasaemia. Lancet. 1998;352(9121):26-29. Not sensitivity or specificity of an identified test. [pmid: 9800742].
Volta U, De Franceschi L, Molinaro N, et al. Frequency and significance of anti-gliadin and anti-endomysial antibodies in autoimmune hepatitis. Digestive Diseases and Sciences. 1998;43(10):2190-2195. Not sensitivity or specificity of an identified test. [pmid: 9790453].
Volta U, De Franceschi L, Molinaro N, et al. Organ-specific autoantibodies in coeliac disease: do they represent an epiphenomenon or the expression of associated autoimmune disorders?. Italian Journal of Gastroenterology and Hepatology. 1997;29(1):18-21. Not sensitivity or specificity of an identified test. [pmid: 9265573].
Volta U, De Giorgio R, Petrolini N, et al. Clinical findings and anti-neuronal antibodies in coeliac disease with neurological disorders. Scandinavian Journal of Gastroenterology. 2002;37(11):1276-1281. Not sensitivity or specificity of an identified test. [pmid: 12465725].
Volta U, Granito A, De Franceschi L, et al. Anti tissue transglutaminase antibodies as predictors of silent coeliac disease in patients with hypertransaminasaemia of unknown origin. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2001;33(5):420-425. Not sensitivity or specificity of an identified test. [pmid: 11529654].
Volta U, Lazzari R, Bianchi F B, et al. Antibodies to dietary antigens in coeliac disease. Scandinavian Journal of Gastroenterology. 1986;21(8):935-940. Not sensitivity or specificity of an identified test. [pmid: 3775259].
Volta U, Lazzari R, Guidetti C S, et al. Multicenter study on the reproducibility of antigliadin (AGA) and antiendomysial antibodies (EmA) in celiac sprue screening. The Tenue Club Group. Journal of Clinical Gastroenterology. 1994;19(1):81-82. Improper control group. [pmid: 7930442].
Volta U, Lenzi M, Lazzari R, et al. Antibodies to gliadin detected by immunofluorescence and a micro-ELISA method: markers of active childhood and adult coeliac disease. Gut. 1985;26(7):667-671. Improper control group. [pmid: 3894169]. [pmcid: 1432992].
Volta U, Molinaro N, De Franceschi L, et al. Human umbilical cord as substrate for IgA antiendomysial antibodies allows large scale screening for celiac sprue. Journal of Clinical Gastroenterology. 1996;23(1):18-20. Improper control group. [pmid: 8835893].
Volta U, Molinaro N, De Franceschi L, et al. IFL- and ELISA-antigliadin antibodies recognize different antigenic reactivities from those of R1-antireticulin and antiendomysial antibodies. Italian Journal of Gastroenterology. 1995;27(2):64-68. Not sensitivity or specificity of an identified test. [pmid: 7579593].
Volta U, Molinaro N, De Franchis R, et al. Correlation between IgA antiendomysial antibodies and subtotal villous atrophy in dermatitis herpetiformis. Journal of Clinical Gastroenterology. 1992;14(4):298-301. Not sensitivity or specificity of an identified test. [pmid: 1607605].
Volta U, Molinaro N, Fratangelo D, et al. IgA antibodies to jejunum. Specific immunity directed against target organ of gluten-sensitive enteropathy. Digestive Diseases and Sciences. 1994;39(9):1924-1929. Not sensitivity or specificity of an identified test. [pmid: 8082498].
Volta U, Molinaro N, Fratangelo D, et al. IgA subclass antibodies to gliadin in serum and intestinal juice of patients with coeliac disease. Clinical and Experimental Immunology. 1990;80(2):192-195. Improper control group. [pmid: 2357845]. [pmcid: 1535301].
Volta U, Molinaro N, Fusconi M, et al. IgA antiendomysial antibody test. A step forward in celiac disease screening. Digestive Diseases and Sciences. 1991;36(6):752-756. Improper control group. [pmid: 2032516].
Volta U, Ravaglia G, Granito A, et al. Coeliac disease in patients with autoimmune thyroiditis. Digestion. 2001;64(1):61-65. Not sensitivity or specificity of an identified test. [pmid: 11549838].
Volta Umberto, Rodrigo Luis, Granito Alessandro, et al. Celiac disease in autoimmune cholestatic liver disorders. American Journal of Gastroenterology. 2002;97(10):2609-2613. Not sensitivity or specificity of an identified test. [pmid: 12385447].
Voutilainen M, Juhola M, Farkkila M, et al. Gastric metaplasia and chronic inflammation at the duodenal bulb mucosa. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2003;35(2):94-98. Not sensitivity or specificity of an identified test. [pmid: 12747627].
Vuoristo M, Miettinen T A. Enhanced synthesis of cholesterol and its precursors in jejunal mucosa in coeliac disease. Gut. 1986;27(4):399-404. Not sensitivity or specificity of an identified test. [pmid: 3792914]. [pmcid: 1433389].
Vuoristo M, Tarpila S, Miettinen T A. Serum lipids and fecal steroids in patients with celiac disease: Effects of gluten-free diet and cholestyramine. Gastroenterology. 1980;78(6):1518-1525. Not sensitivity or specificity of an identified test. [pmid: 7372070].
Wachtel M S, Thaler H T, Gangi M D, et al. Immunoperoxidase staining of cervicovaginal smears after radiotherapy. Acta Cytologica. 1992;36(3):305-309. Not sensitivity or specificity of an identified test. [pmid: 1580112].
Wade J A F, Hurley C K, Hastings A, et al. Combinatorial diversity in DR2 haplotypes. Tissue Antigens. 1993;41(3):113-118. Not sensitivity or specificity of an identified test. [pmid: 8316942].
Wahab P J, Crusius J B, Meijer J W, et al. Gluten challenge in borderline gluten-sensitive enteropathy. American Journal of Gastroenterology. 2001;96(5):1464-1469. Not sensitivity or specificity of an identified test. [pmid: 11374684].
Wahab P J, Crusius J B, Meijer J W, et al. Cyclosporin in the treatment of adults with refractory coeliac disease--an open pilot study. Alimentary Pharmacology & Therapeutics. 2000;14(6):767-774. Not sensitivity or specificity of an identified test. [pmid: 10848661].
Wahab P J, Meijer J W R, Goerres M S, et al. Coeliac disease: changing views on gluten-sensitive enteropathy. Scandinavian Journal of Gastroenterology. Supplement. 2002;(236):60-65. Not sensitivity or specificity of an identified test.
Wahab P J, Peters W H, Roelofs H M, et al. Glutathione S-transferases in small intestinal mucosa of patients with coeliac disease. Japanese Journal of Cancer Research - Gann. 2001;92(3):279-284. Not sensitivity or specificity of an identified test. [pmid: 11267937].
Wahab Peter J, Meijer Jos W R, Mulder Chris J J. Histologic follow-up of people with celiac disease on a gluten-free diet: slow and incomplete recovery. American Journal of Clinical Pathology. 2002;118(3):459-463. Not sensitivity or specificity of an identified test. [pmid: 12219789].
Wahab Peter J, Meijer Jos W R, Dumitra Daniela, et al. Coeliac disease: more than villous atrophy. Romanian Journal of Gastroenterology. 2002;11(2):121-127. Not sensitivity or specificity of an identified test. [pmid: 12145668].
Wahnschaffe U, Stockmann M, Daum S et al. Intestinal antibodies against gliadin, tissue-transglutaminase, beta-lactoglobulin, and ovalbumin in patients with irritable bowel syndrome. Annals of the New York Academy of Sciences 1998;859280–284. Not sensitivity or specificity of an identified test
Wahnschaffe U, Ullrich R, Riecken E O, et al. Celiac disease-like abnormalities in a subgroup of patients with irritable bowel syndrome. Gastroenterology. 2001;121(6):1329-1338. Not sensitivity or specificity of an identified test. [pmid: 11729112].
Wakita H, Takigawa M. Activation of epidermal growth factor receptor promotes late terminal differentiation of cell-matrix interaction-disrupted keratinocytes. Journal of Biological Chemistry. 1999;274(52):37285-37291. Not sensitivity or specificity of an identified test. [pmid: 10601294].
Walia B N, Mehta S, Gupte S P. Caeliac disease. Indian Pediatrics. 1972;9(1):16-19. Not sensitivity or specificity of an identified test. [pmid: 5034307].
Walker A M, Montgomery D W, Saraiya S, et al. Prolactin-immunoglobulin G complexes from human serum act as costimulatory ligands causing proliferation of malignant B lymphocytes. Proceedings of the National Academy of Sciences of the United States of America. 1995;92(8):3278-3282. Not sensitivity or specificity of an identified test. [pmid: 7724552]. [pmcid: 42149].
Walker Michael G. Z39Ig is co-expressed with activated macrophage genes. Biochimica Et Biophysica Acta. 2002;1574(3):387-390. Not sensitivity or specificity of an identified test. [pmid: 11997108].
Walker-Smith J, Kilby A. Small intestinal histology in coeliac disease. Lancet. 1975;2(7925):132. Not sensitivity or specificity of an identified test. [pmid: 49729].
Walker-Smith J. Cow's milk protein intolerance. Transient food intolerance of infancy. Archives of Disease in Childhood. 1975;50(5):347-350. Not sensitivity or specificity of an identified test. [pmid: 1211956].
Walker-Smith J. Transient gluten intolerance. Archives of Disease in Childhood. 1970;45(242):523-526. Not sensitivity or specificity of an identified test. [pmid: 5506937].
Walker-Smith J. Food sensitive enteropathy: Overview and update. Acta Paediatr Jpn Overs Ed. 1994;36(5):545-549. Not sensitivity or specificity of an identified test.
Walker-Smith J A. Small bowel morphology in childhood. Medical Journal of Australia. 1969;1(8):382-387. Not sensitivity or specificity of an identified test. [pmid: 5782084].
Walker-Smith J A. Celiac disease and Down syndrome. Journal of Pediatrics. 2000;137(6):743-744. Not sensitivity or specificity of an identified test. [pmid: 11113826].
Walker-Smith J A. Immune function of small bowel and its related diseases. Acta Paediatr Taiwan. 2000;41(4):177-178. Not sensitivity or specificity of an identified test. [pmid: 11021001].
Walker-Smith J A, Grigor W. Coeliac disease in a diabetic child. Lancet. 1969;1(7603):1021. Not sensitivity or specificity of an identified test. [pmid: 4185626].
Walker-Smith J A, Reye R D. Small intestinal morphology in aboriginal children. Australian and New Zealand Journal of Medicine. 1971;1(4):377-384. Not sensitivity or specificity of an identified test. [pmid: 5292994].
Walker-Smith J A, Guandalini S, Schmitz J, et al. Revised criteria for diagnosis of coeliac disease. Arch Dis Child. 1990;65(8):909-911. Serology <1990. [pmid: 2205160].
Walker-Smith J A, Vines R, Grigor W. Coeliac disease and diabetes. Lancet. 1969;2(7621):650. Not sensitivity or specificity of an identified test. [pmid: 4185626].
Walker-Smith J, Kilby A. Letter: Small-intestinal histology in coeliac disease. Lancet. 1975;2(7925):132. Not sensitivity or specificity of an identified test. [pmid: 49729].
Walker-Smith J, Walker W A. The development of pediatric gastroenterology: A historical overview. Pediatric Research. 2003;53(4):706-715. Not sensitivity or specificity of an identified test. [pmid: 12612197].
Walkowiak J, Herzig K H. Fecal elastase-1 is decreased in villous atrophy regardless of the underlying disease. European Journal of Clinical Investigation. 2001;31(5):425-430. Not sensitivity or specificity of an identified test. [pmid: 11589722].
Wall A J, Levinson J D, Refetoff S. Hyperthyroidism and adult celiac disease. American Journal of Gastroenterology. 1973;60(4):387-393. Not sensitivity or specificity of an identified test. [pmid: 4758296].
Wallaschofski H, Meyer A, Tuschy U, et al. HLA-DQA1*0301-associated susceptibility for autoimmune polyglandular syndrome type II and III. Hormone and Metabolic Research.Hormon- Und Stoffwechselforschung. Hormones Et Metabolisme. 2003;35(2):120-124. Not sensitivity or specificity of an identified test. [pmid: 12734793].
Walsh C H, Cooper B T, Wright A D, et al. Diabetes mellitus and coeliac disease: a clinical study. Quarterly Journal of Medicine. 1978;47(185):89-100. Not sensitivity or specificity of an identified test. [pmid: 674552].
Walsh L J, Goerdt S, Pober J S, et al. MS-1 sinusoidal endothelial antigen is expressed by factor XIIIa+, HLA-DR+ dermal perivascular dendritic cells. Laboratory Investigation 1991;A Journal of Technical Methods and Pathology; 65(6):732–741. Not sensitivity or specificity of an identified test
Walter M, Albert E, Conrad M, et al. IDDM2/insulin VNTR modifies risk conferred by IDDM1/HLA for development of Type 1 diabetes and associated autoimmunity. Diabetologia. 2003;46(5):712-720. Not sensitivity or specificity of an identified test. [pmid: 12750767].
Walters J R, Banks L M, Butcher G P, et al. Detection of low bone mineral density by dual energy x ray absorptiometry in unsuspected suboptimally treated coeliac disease. Gut. 1995;37(2):220-224. Not sensitivity or specificity of an identified test. [pmid: 7557572]. [pmcid: 1382722].
Walz R, Koch H K. Malignant pleural mesothelioma: some aspects of epidemiology, differential diagnosis and prognosis. Histological and immunohistochemical evaluation and follow-up of mesotheliomas diagnosed from 1964 to January 1985. Pathology, Research and Practice. 1990;186(1):124-134. Not sensitivity or specificity of an identified test. [pmid: 1690413].
Wan X H, Lee E H, Koh H J, et al. Enhanced expression of transglutaminase 2 in anterior polar cataracts and its induction by TGF-beta in vitro. British Journal of Ophthalmology. 2002;86(11):1293-1298. Not sensitivity or specificity of an identified test. [pmid: 12386092]. [pmcid: 1771348].
Wang M, Kim I G, Steinert P M, et al. Assignment of the human transglutaminase 2 (TGM2) and transglutaminase 3 (TGM3) genes to chromosome 20q11.2. Genomics. 1994;23(3):721-722. Not sensitivity or specificity of an identified test. [pmid: 7851911].
Wang N, Dumot J A, Achkar E, et al. Colonic epithelial lymphocytosis without a thickened subepithelial collagen table: a clinicopathologic study of 40 cases supporting a heterogeneous entity. American Journal of Surgical Pathology. 1999;23(9):1068-1074. Not sensitivity or specificity of an identified test. [pmid: 10478666].
Wankiewicz Anna, Iwan-Zietek Iza, Gwiezdzinski Zenon, et al. Levels of F(1+2) prothrombin fragments and thrombin - antithrombin III (TAT) complexes in patients with dermatitis herpetiformis. Medical Science Monitor - International Medical Journal of Experimental and Clinical Research. 2002;8(8):Br324-Br327. Not sensitivity or specificity of an identified test. [pmid: 12165736].
Warngard O, Stenhammar L, Ascher L, et al. Small bowel biopsy in Swedish paediatric clinics. Acta Paediatrica (Oslo, Norway - 1992). 1996;85(2):240-241. Not sensitivity or specificity of an identified test. [pmid: 8640058].
Warshaw A L, Laster L. Protein synthesis by human intestinal mucosa: variations with diseases of the gut. Journal of Surgical Research. 1973;14(4):285-293. Not sensitivity or specificity of an identified test. [pmid: 4121932].
Watson A J, Parkin J M. Jejunal-biopsy findings during prodromal stage of measles in a child with coeliac disease. Lancet. 1970;2(7683):1134-1135. Not sensitivity or specificity of an identified test. [pmid: 4097933].
Watson A J, Wright N A. Morphology and cell kinetics of the jejunal mucosa in untreated patients. Clin Gastroenterol. 1974;3(1):11-31. Not sensitivity or specificity of an identified test. [pmid: 4600564].
Watson A J, Appleton D R, Wright N A. Adaptive cell-proliferative changes in the small-intestinal mucosa in coeliac disease. Scandinavian Journal of Gastroenterology.Supplement 1982;74115–127. Not sensitivity or specificity of an identified test
Watson R G, McMillan S A, Dickey W, et al. Detection of undiagnosed coeliac disease with atypical features using antireticulin and antigliadin antibodies. Quarterly Journal of Medicine. 1992;84(305):713-718. Not sensitivity or specificity of an identified test. [pmid: 1303650].
Watson R G, McMillan S A, Dolan C, et al. Gliadin antibody detection in gluten enteropathy. Ulster Medical Journal. 1986;55(2):160-164. Serology <1990. [pmid: 3811015].
Wauters E A. Clinical diagnosis of coeliac disease. Irish Medical Journal. 1974;67(15):406-411. Not sensitivity or specificity of an identified test. [pmid: 4412468].
Wauters E A, Jansen J, Houwen R H, et al. Serum IgG and IgA anti-gliadin antibodies as markers of mucosal damage in children with suspected celiac disease upon gluten challenge. Journal of Pediatric Gastroenterology and Nutrition. 1991;13(2):192-196. Not sensitivity or specificity of an identified test. [pmid: 1941413].
Weetman A P, McCorkle R. Evidence against extended DR3-related haplotypes in Graves' disease. Journal of Immunogenetics. 1990;17(6):403-407. Not sensitivity or specificity of an identified test. [pmid: 1982883].
Wehbi Nizar K, Dugger Ashley L, Bonner Rebecca B, et al. Pan-cadherin as a high level phenotypic biomarker for prostate cancer. Journal of Urology. 2002;167(5):2215-2221. Not sensitivity or specificity of an identified test. [pmid: 11956481].
Wei L, Debets R, Hegmans J J, et al. IL-1 beta and IFN-gamma induce the regenerative epidermal phenotype of psoriasis in the transwell skin organ culture system. IFN-gamma up-regulates the expression of keratin 17 and keratinocyte transglutaminase via endogenous IL-1 production. Journal of Pathology. 1999;187(3):358-364. Not sensitivity or specificity of an identified test. [pmid: 10398092].
Weile B. Aspects of classic symptomatic childhood coeliac disease in Denmark: Retrospectively illustrated by local, regional, and national studies. Apmis Suppl. 2003;111(113):5-46. Not sensitivity or specificity of an identified test. [pmid: 14626049].
Weile B, Grodzinsky E, Skogh T et al. Screening Danish blood donors for antigliadin and antiendomysium antibodies. Acta paediatrica (Oslo, Norway : 1992).Supplement 1996;41246Not sensitivity or specificity of an identified test
Weile B, Hansen B F, Hagerstrand I, et al. Interobserver variation in diagnosing coeliac disease. A joint study by Danish and Swedish pathologists. Apmis - Acta Pathologica, Microbiologica, Et Immunologica Scandinavica. 2000;108(5):380-384. Unable to extract data. [pmid: 10937777].
Weile Birgitte, Heegaard Niels H H, Hoier-Madsen Mimi, et al. Tissue transglutaminase and endomysial autoantibodies measured in an historical cohort of children and young adults in whom coeliac disease was suspected. European Journal of Gastroenterology & Hepatology. 2002;14(1):71-76. Improper control group. [pmid: 11782578].
Weile I, Grodzinsky E, Skogh T, et al. High prevalence rates of adult silent coeliac disease, as seen in Sweden, must be expected in Denmark. Apmis - Acta Pathologica, Microbiologica, Et Immunologica Scandinavica. 2001;109(11):745-750. Not sensitivity or specificity of an identified test. [pmid: 11900053].
Weinberg J B, Pippen A M, Greenberg C S. Extravascular fibrin formation and dissolution in synovial tissue of patients with osteoarthritis and rheumatoid arthritis. Arthritis and Rheumatism. 1991;34(8):996-1005. Not sensitivity or specificity of an identified test. [pmid: 1677574].
Weinshenker B G, Santrach P, Bissonet A S, et al. Major histocompatibility complex class II alleles and the course and outcome of MS: a population-based study. Neurology. 1998;51(3):742-747. Not sensitivity or specificity of an identified test. [pmid: 9748020].
Weinstein W M. Latent celiac sprue. Gastroenterology. 1974;66(4):489-493. Not sensitivity or specificity of an identified test. [pmid: 4821074].
Weinstein W M, Brow J R, Parker F, et al. The small intestinal mucosa in dermatitis herpetiformis. II. Relationship of the small intestinal lesion to gluten. Gastroenterology. 1971;60(3):362-369. Not sensitivity or specificity of an identified test. [pmid: 5554078].
Weinstein W M, Saunders D R, Tytgat G N, et al. Collagenous sprue--an unrecognized type of malabsorption. New England Journal of Medicine. 1970;283(24):1297-1301. Not sensitivity or specificity of an identified test. [pmid: 5478450].
Weir D G, Hourihane D O. Coeliac disease during the teenage period: the value of serial serum folate estimations. Gut. 1974;15(6):450-457. Not sensitivity or specificity of an identified test. [pmid: 4851068]. [pmcid: 1413001].
Weiser M M, Douglas A P. An alternative mechanism for gluten toxicity in coeliac disease. Lancet. 1976;1(7959):567-569. Not sensitivity or specificity of an identified test. [pmid: 55842].
Weiss J B, Austin R K, Schanfield M S, et al. Gluten-sensitive enteropathy. Immunoglobulin G heavy-chain (Gm) allotypes and the immune response to wheat gliadin. Journal of Clinical Investigation. 1983;72(1):96-101. Not sensitivity or specificity of an identified test. [pmid: 6409931]. [pmcid: 1129164].
Weizman Z, Ben Zion Y Z, Binsztok M, et al. Correlation of clinical characteristics and small bowel histopathology in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1997;24(5):555-558. Not sensitivity or specificity of an identified test. [pmid: 9161951].
Weizman Z, Stringer D A, Durie P R. Radiologic manifestations of malabsorption: a nonspecific finding. Pediatrics. 1984;74(4):530-533. Not sensitivity or specificity of an identified test. [pmid: 6483519].
Weizman Z, Vardi O, Binsztok M. Dermatoglyphic (fingerprint) patterns in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1990;10(4):451-453. Not sensitivity or specificity of an identified test. [pmid: 2358976].
Welcher B C, Carra J H, DaSilva L, et al. Lethal shock induced by streptococcal pyrogenic exotoxin A in mice transgenic for human leukocyte antigen-DQ8 and human CD4 receptors: Implications for development of vaccines and therapeutics. J Infect Dis. 2002;186(4):501-510. Not sensitivity or specificity of an identified test. [pmid: 12195377].
Weller M, Esser P, Bresgen M, et al. Thrombospondin: a new attachment protein in preretinal traction membranes. European Journal of Ophthalmology. 1992;2(1):10-14. Not sensitivity or specificity of an identified test. [pmid: 1353387].
Wellman-Bednawska M, Artur Y, Siest G. Variations in sialic acid content of gamma-glutamyltransferase: a consequence for immunochemical determinations?. Clinica Chimica Acta 1985;International Journal of Clinical Chemistry; 148(1):21–30. Not sensitivity or specificity of an identified test
Wells C A, Heryet A, Brochier J, et al. The immunocytochemical detection of axillary micrometastases in breast cancer. British Journal of Cancer. 1984;50(2):193-197. Not sensitivity or specificity of an identified test. [pmid: 6380553].
Welsh J D, Zschiesche O M, Anderson J, et al. Intestinal disaccharidase activity in celiac sprue (gluten-sensitive enteropathy). Archives of Internal Medicine. 1969;123(1):33-38. Not sensitivity or specificity of an identified test. [pmid: 5761736].
West J, Lloyd C A, Hill P G, et al. IgA-antitissue transglutaminase: validation of a commercial assay for diagnosing coeliac disease. Clinical Laboratory. 2002;48(56):241-246. Improper control group. [pmid: 12071574].
West J, Logan R F A, Hill P G, et al. Seroprevalence, correlates, and characteristics of undetected coeliac disease in England. Gut. 2003;52(7):960-965. Not sensitivity or specificity of an identified test. [pmid: 12801951]. [pmcid: 1773707].
Westergaard H. The sprue syndromes. American Journal of the Medical Sciences. 1985;290(6):249-262. Not sensitivity or specificity of an identified test. [pmid: 3909813].
Westerholm-Ormio M, Garioch J, Ketola I, et al. Inflammatory cytokines in small intestinal mucosa of patients with potential coeliac disease. Clinical and Experimental Immunology. 2002;128(1):94-101. Not sensitivity or specificity of an identified test. [pmid: 11982596]. [pmcid: 1906370].
Westerholm-Ormio Mia, Vaarala Outi, Pihkala Paivi, et al. Immunologic activity in the small intestinal mucosa of pediatric patients with type 1 diabetes. Diabetes. 2003;52(9):2287-2295. Not sensitivity or specificity of an identified test. [pmid: 12941768].
Westphal J R, Boerbooms A M, Schalwijk C J, et al. Anti-endothelial cell antibodies in sera of patients with autoimmune diseases: comparison between ELISA and FACS analysis. Clinical and Experimental Immunology. 1994;96(3):444-449. Not sensitivity or specificity of an identified test. [pmid: 8004814]. [pmcid: 1534560].
Wharton B A. Coeliac disease in childhood. Br J Hosp Med. 1974;12(4):452-466. Not sensitivity or specificity of an identified test.
White A G, Barnetson R S C, Da Costa J A A, et al. The incidence of HL A antigens in dermatitis herpetiformis. Br J Dermatol. 1973;89(2):133-136. Not sensitivity or specificity of an identified test. [pmid: 4726888].
Whitlow M B, Ramm L E, Mayer M M. Penetration of C8 and C9 in the C5b-9 complex across the erythrocyte membrane into the cytoplasmic space. Journal of Biological Chemistry. 1985;260(2):998-1005. Not sensitivity or specificity of an identified test. [pmid: 2857173].
Whyard T C, Ablin R J. A tissue type transglutaminase in human seminal plasma. American Journal of Reproductive Immunology (New York, N.y.- 1989). 1997;38(6):391-399. Not sensitivity or specificity of an identified test. [pmid: 9412722].
Whyard T C, Ablin R J. A modified assay for blood coagulation factor XIII using enzyme immobilisation on Staphylococcus aureus: Preliminary evaluation. Fibrinolysis. 1991;5(2):127-130. Not sensitivity or specificity of an identified test.
Wiedmann M, Liebert U G, Oesen U, et al. Decreased immunogenicity of recombinant hepatitis B vaccine in chronic hepatitis C. Hepatology. 2000;31(1):230-234. Not sensitivity or specificity of an identified test. [pmid: 10613751].
Willems D, Cadranel S, Jacobs W. Measurement of urinary sugars by HPLC in the estimation of intestinal permeability: Evaluation in pediatric clinical practice. Clinical Chemistry. 1993;39(5):888-890. Not sensitivity or specificity of an identified test. [pmid: 8485882].
Williams A J, Annis P, Lock R J, et al. Evaluation of a high-throughput second antibody radiobinding assay for measuring IgA antibodies to human tissue transglutaminase. Journal of Immunological Methods. 1999;228(12):81-85. Improper control group. [pmid: 10556545].
Williams A J, Norcross A J, Lock R J, et al. The high prevalence of autoantibodies to tissue transglutaminase in first-degree relatives of patients with type 1 diabetes is not associated with islet autoimmunity. Diabetes Care. 2001;24(3):504-509. Not sensitivity or specificity of an identified test. [pmid: 11289476].
Williams C N. Celiac disease: Past, present and future. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 1997;11(8):647-649. Not sensitivity or specificity of an identified test. [pmid: 9459042].
Williams C N. Collagenous colitis. Canadian Journal of Gastroenterology = Journal Canadien De Gastroenterologie. 1998;12(1):23-24. Not sensitivity or specificity of an identified test. [pmid: 9544408].
Williamson Debbie, Marsh Michael N. Celiac disease. Molecular Biotechnology. 2002;22(3):293-299. Not sensitivity or specificity of an identified test. [pmid: 12448883].
Williamson N, Asquith P, Stokes L, et al. Anticonnective tissue and other antitissue ‘antibodies’ in the sera of patients with coeliac disease compared with the findings in a mixed hospital population. Journal of Clinical Pathology. 1976;29(6):484-494. Not sensitivity or specificity of an identified test. [pmid: 939804]. [pmcid: 476105].
Willoughby J M T, Laitner S M. Audit of the investigation of iron deficiency anaemia in a distinct general hospital, with sample guidelines for future practice. Postgrad Med J. 2000;76(894):218-222. Not sensitivity or specificity of an identified test. [pmid: 10727565].
Wills A J, Turner B, Lock R J, et al. Dermatitis herpetiformis and neurological dysfunction. Journal of Neurology, Neurosurgery, and Psychiatry. 2002;72(2):259-261. Not sensitivity or specificity of an identified test. [pmid: 11796779].
Wilson A G, Clay F E, Crane A M, et al. Comparative genetic association of human leukocyte antigen class II and tumor necrosis factor-alpha with dermatitis herpetiformis. J Invest Dermatol. 1995;104(5):856-858. Not sensitivity or specificity of an identified test. [pmid: 7738367].
Wilson A G, Symons J A, McDowell T L, et al. Effects of a polymorphism in the human tumor necrosis factor alpha promoter on transcriptional activation. Proc Natl Acad Sci U S A. 1997;94(7):3195-3199. Not sensitivity or specificity of an identified test. [pmid: 9096369]. [pmcid: 20345].
Wilson C, Eade O E, Elstein M, et al. Subclinical coeliac disease and infertility. Br Med J. 1976;2(6029):215-216. Not sensitivity or specificity of an identified test. [pmid: 974499].
Wilson W B. Clinical and laboratory evaluation of malabsorption. Journal of the Mississippi State Medical Association. 1978;19(10):183-185. Not sensitivity or specificity of an identified test. [pmid: 712824].
Wingren U, Hallert C, Norrby K, et al. Histamine and mucosal mast cells in gluten enteropathy. Agents and Actions. 1986;18(12):266-268. Not sensitivity or specificity of an identified test. [pmid: 3728211].
Winklhofer-Roob B M, Rossipal E, Lanzer G. Human leucocyte class I and II antigens in coeliac disease: a study in an Austrian paediatric population. European Journal of Pediatrics. 1991;150(10):704-707. Not sensitivity or specificity of an identified test. [pmid: 1915480].
Wirtz P W, Roep B O, Schreuder G M T, et al. HLA class I and II in Lambert-Eaton myasthenic syndrome without associated tumor. Hum Immunol. 2001;62(8):809-813. Not sensitivity or specificity of an identified test. [pmid: 11476904].
Witas H W. Genetic background of coeliac disease. Cent-Eur J Immunol. 2000;25(4):222-226. Not sensitivity or specificity of an identified test.
Witas H W, Mlynarski W, Niewiadomska H, et al. Immune response in coeliac disease: Involvement of costimulatory molecules during activation of lymphocytes infiltrating the intestine. Cent-Eur J Immunol. 2000;25(4):180-184. Not sensitivity or specificity of an identified test.
Witas H W, Mlynarski W, Rozalski M, et al. Study of Polish coeliac patients: HLA-DQ amino acid variants involved in antigen presentation. Cent-Eur J Immunol. 1997;22(4):266-271. Not sensitivity or specificity of an identified test.
Witas H W, Sychowski R, Mlynarski W, et al. Does TNF locus contribute to coeliac disease as the independent genetic factor or linked to particular HLA-haplotype?. Cent-Eur J Immunol. 2000;25(2):57-62. Not sensitivity or specificity of an identified test.
Wolber R, Owen D, Freeman H. Colonic lymphocytosis in patients with celiac sprue. Human Pathology. 1990;21(11):1092-1096. Not sensitivity or specificity of an identified test. [pmid: 2227917].
Wolber R, Owen D, DelBuono L, et al. Lymphocytic gastritis in patients with celiac sprue or spruelike intestinal disease. Gastroenterology. 1990;98(2):310-315. Not sensitivity or specificity of an identified test. [pmid: 2295386].
Wong F S, Wen L. The study of HLA class II and autoimmune diabetes. Curr Mol Med. 2003;3(1):1-15. Not sensitivity or specificity of an identified test. [pmid: 12558070].
Wong R C W, Steele R H, Reeves G E M, et al. Antibody and genetic testing in coeliac disease. Pathology. 2003;35(4):285-304. Not sensitivity or specificity of an identified test. [pmid: 12959764].
Wong R C W, Wilson R J, Steele R H, et al. A comparison of 13 guinea pig and human anti-tissue transglutaminase antibody ELISA kits. Journal of Clinical Pathology. 2002;55(7):488-494. Improper control group. [pmid: 12101191]. [pmcid: 1769686].
Wood G M, Howdle P D, Trejdosiewicz L K, et al. Jejunal plasma cells and in vitro immunoglobulin production in adult coeliac disease. Clinical and Experimental Immunology. 1987;69(1):123-132. Not sensitivity or specificity of an identified test. [pmid: 3652527]. [pmcid: 1542244].
Wood G M, Shires S, Howdle P D, et al. Immunoglobulin production by coeliac biopsies in organ culture. Gut. 1986;27(10):1151-1160. Not sensitivity or specificity of an identified test. [pmid: 3781327]. [pmcid: 1433866].
Woodley J F. Pyrrolidonecarboxylyl peptidase activity in normal intestinal biopsies and those from coeliac patients. Clinica Chimica Acta 1972;International Journal of Clinical Chemistry; 42(1):211–213. Not sensitivity or specificity of an identified test
Woolley N, Holopainen P, Bourgain C, et al. CD80 (B7-1) and CD86 (B7-2) genes and genetic susceptibility to coeliac disease. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 2002;29(4):331-333. Not sensitivity or specificity of an identified test. [pmid: 12121279].
Woolley Niina, Holopainen Paivi, Ollikainen Vesa, et al. A new locus for coeliac disease mapped to chromosome 15 in a population isolate. Human Genetics. 2002;111(1):40-45. Not sensitivity or specificity of an identified test. [pmid: 12136234].
Wordsworth B P, Salmon M. The HLA class II component of susceptibility to rheumatoid arthritis. Bailliere's Clin Rheumatol. 1992;6(2):325-336. Not sensitivity or specificity of an identified test. [pmid: 1525842].
Wordsworth P. PCR-SSO typing in HLA-disease association studies. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1991;18(12):139-146. Not sensitivity or specificity of an identified test. [pmid: 2069941].
Wozniak M, Fausto A, Carron C P, et al. Mechanically strained cells of the osteoblast lineage organize their extracellular matrix through unique sites of alphavbeta3-integrin expression. Journal of Bone and Mineral Research - the Official Journal of the American Society for Bone and Mineral Research. 2000;15(9):1731-1745. Not sensitivity or specificity of an identified test. [pmid: 10976993].
Wray D. Gluten-sensitive recurrent aphthous stomatitis. Digestive Diseases and Sciences. 1981;26(8):737-740. Not sensitivity or specificity of an identified test. [pmid: 7261838].
Wright D H. Enteropathy associated T cell lymphoma. Cancer Surveys 1997;30249–261. Not sensitivity or specificity of an identified test
Wright N A, Motley A R, Appleton D R, et al. Measurement of cell production rate in the human small bowel. Pathologia Et Microbiologia. 1973;39(3):251-253. Not sensitivity or specificity of an identified test. [pmid: 4718564].
Wright N, Watson A, Morley A, et al. Cell kinetics in flat (avillous) mucosa of the human small intestine. Gut. 1973;14(9):701-710. Not sensitivity or specificity of an identified test. [pmid: 4752034]. [pmcid: 1412777].
Wright P H, Menzies I S, Pounder R E, et al. Adult idiopathic pulmonary haemosiderosis and coeliac disease. Quarterly Journal of Medicine. 1981;50(197):95-102. Not sensitivity or specificity of an identified test. [pmid: 7267971].
Wu T T, Hamilton S R. Lymphocytic gastritis: association with etiology and topology. American Journal of Surgical Pathology. 1999;23(2):153-158. Not sensitivity or specificity of an identified test. [pmid: 9989841].
Wucherpfennig K W. Insights into autoimmunity gained from structural analysis of MHC-peptide complexes. Current Opinion in Immunology. 2001;13(6):650-656. Not sensitivity or specificity of an identified test. [pmid: 11677085].
Wurm P, Wicks A C. Iron deficiency anaemia - A clinical challenge. Postgrad Med J. 2000;76(894):193-194. Not sensitivity or specificity of an identified test. [pmid: 11009583].
Wyckoff E E, Croall D E, Ehrenfeld E. The p220 component of eukaryotic initiation factor 4F is a substrate for multiple calcium-dependent enzymes. Biochemistry. 1990;29(43):10055-10061. Not sensitivity or specificity of an identified test. [pmid: 1980214].
Yadollahi-Farsani Masoud, Davies Donald S, Boobis Alan R. The mutational signature of alpha-hydroxytamoxifen at Hprt locus in Chinese hamster cells. Carcinogenesis. 2002;23(11):1947-1952. Not sensitivity or specificity of an identified test. [pmid: 12419845].
Yagui-Beltran A, Craig A L, Lawrie L, et al. The human oesophageal squamous epithelium exhibits a novel type of heat shock protein response. European Journal of Biochemistry / Febs. 2001;268(20):5343-5355. Not sensitivity or specificity of an identified test. [pmid: 11606197].
Yamada K, Matsuki M, Morishima Y, et al. Activation of the human transglutaminase 1 promoter in transgenic mice: terminal differentiation-specific expression of the TGM1-lacZ transgene in keratinized stratified squamous epithelia. Human Molecular Genetics. 1997;6(13):2223-2231. Not sensitivity or specificity of an identified test. [pmid: 9361026].
Yamada K, Yamanishi K, Kakizuka A, et al. Transcriptional regulation of human transglutaminase1 gene by signaling systems of protein kinase C, RAR/RXR and Jun/Fos in keratinocytes. Biochemistry and Molecular Biology International. 1994;34(4):827-836. Not sensitivity or specificity of an identified test. [pmid: 7866310].
Yamada T, Yoshiyama Y, Kawaguchi N, et al. Possible roles of transglutaminases in Alzheimer's disease. Dementia and Geriatric Cognitive Disorders. 1998;9(2):103-110. Not sensitivity or specificity of an identified test. [pmid: 9524802].
Yamanishi K, Inazawa J, Liew F M, et al. Structure of the gene for human transglutaminase 1. Journal of Biological Chemistry. 1992;267(25):17858-17863. Not sensitivity or specificity of an identified test. [pmid: 1381356].
Yan S D, Huang C C. Lymphotoxin in human middle ear cholesteatoma. Laryngoscope. 1991;101(4 Pt 1):411-415. Not sensitivity or specificity of an identified test. [pmid: 1680210].
Yan S D, Huang C C. Tumor necrosis factor alpha in middle ear cholesteatoma and its effect on keratinocytes in vitro. Annals of Otology, Rhinology, and Laryngology. 1991;100(2):157-161. Not sensitivity or specificity of an identified test.
Yan Z H, Noonan S, Nagy L, et al. Retinoic acid induction of the tissue transglutaminase promoter is mediated by a novel response element. Mol Cell Endocrinol. 1996;120(2):203-212. Not sensitivity or specificity of an identified test. [pmid: 8832580].
Yanagawa T, Mangklabruks A, Chang Y-B, et al. Human histocompatibility leukocyte antigen-DQA1*0501 allele associated with genetic susceptibility to Graves' disease in a Caucasian population. J Clin Endocrinol Metab. 1993;76(6):1569-1574. Not sensitivity or specificity of an identified test. [pmid: 8501164].
Yang H, Goluszko E, David C, et al. Induction of myasthenia gravis in HLA transgenic mice by immunization with human acetylcholine receptors. Ann New York Acad Sci. 2003;998(-):375-378. Not sensitivity or specificity of an identified test. [pmid: 14592899].
Yao Z, Kimura A, Hartung K, et al. Polymorphism of the DQA1 promoter region (QAP) and DRB1, QAP, DQA1, DQB1 haplotypes in systemic lupus erythematosus. Immunogenetics. 1993;38(6):421-429. Not sensitivity or specificity of an identified test. [pmid: 8406614].
Yaqoob N. Coeliac disease: A local perspective. J Coll Phys Surg Pak. 1999;9(12):526-528. Not sensitivity or specificity of an identified test.
Yazdanbakhsh M, Sartono E, Kruize Y C M, et al. HLA and elephantiasis in lymphatic filariasis. Hum Immunol. 1995;44(1):58-61. Not sensitivity or specificity of an identified test. [pmid: 8522456].
Yeboah F A, White D. AlphaB-crystallin expression in celiac disease - a preliminary study. Croatian Medical Journal. 2001;42(5):523-526. Not sensitivity or specificity of an identified test. [pmid: 11593501].
Yelamos J, Garcia-Lozano J R, Moreno I, et al. Association of HLA-DR4-Dw15 (DRB1*0405) and DR10 with rheumatoid arthritis in a Spanish population. Arthritis Rheum. 1993;36(6):811-814. Not sensitivity or specificity of an identified test. [pmid: 8507223].
Yiannakou J Y, Brett P M, Morris M A, et al. Family linkage study of the T-cell receptor genes in coeliac disease. Italian Journal of Gastroenterology and Hepatology. 1999;31(3):198-201. Not sensitivity or specificity of an identified test. [pmid: 10379479].
Yiannakou J Y, Dell'Olio D, Saaka M, et al. Detection and characterisation of anti-endomysial antibody in coeliac disease using human umbilical cord. International Archives of Allergy and Immunology. 1997;112(2):140-144. Improper control group. [pmid: 9030093].
Yiu C Y, Baker L A, Boulos P B. Immunolocalisation of an anti-EMA monoclonal antibody to a renal carcinoma xenograft. Anticancer Research. 1990;10(6):1775-1778. Not sensitivity or specificity of an identified test. [pmid: 2285258].
Yoneda K, Akiyama M, Morita K, et al. Expression of transglutaminase 1 in human hair follicles, sebaceous glands and sweat glands. British Journal of Dermatology. 1998;138(1):37-44. Not sensitivity or specificity of an identified test. [pmid: 9536221].
Yoneda K, Akiyama M, Shimizu H, et al. Transglutaminase 1 in human hair follicle. Experimental Dermatology. 1999;8(4):368-369. Not sensitivity or specificity of an identified test. [pmid: 10439284].
Yoshiie K, Kim H-Y, Mott J, et al. Intracellular infection by the human granulocytic ehrlichiosis agent inhibits human neutrophil apoptosis. Infect Immun. 2000;68(3):1125-1133. Not sensitivity or specificity of an identified test. [pmid: 10678916]. [pmcid: 97257].
Young G P, Hebbard G S. Diagnostic techniques for small intestinal disease. Curr Opin Gastroenterol. 1992;8(2):232-238. Not sensitivity or specificity of an identified test.
Young G P, Koberts S K. Diagnostic studies of the small intestine. Curr Opin Gastroenterol. 1991;7(2):256-262. Not sensitivity or specificity of an identified test.
Young V L, Nemecek J R, Schwartz B D, et al. HLA typing in women with breast implants. Plast Reconstr Surg. 1995;96(7):1497-1520. Not sensitivity or specificity of an identified test. [pmid: 7480270].
Younoszai M K, Ranshaw J C. Quantitation of intestinal-tissue layers from their histology. American Journal of Digestive Diseases. 1975;20(8):764-770. Not sensitivity or specificity of an identified test. [pmid: 1098450].
Yu B, Gauthier L, Hausmann D H, et al. Binding of conserved islet peptides by human and murine MHC class II molecules associated with susceptibility to type I diabetes. European Journal of Immunology. 2000;30(9):2497-2506. Not sensitivity or specificity of an identified test. [pmid: 11009082].
Yu L, Brewer K W, Gatest S, et al. DRB1*04 and DQ alleles: expression of 21-hydroxylase autoantibodies and risk of progression to Addison's disease. Journal of Clinical Endocrinology and Metabolism. 1999;84(1):328-335. Not sensitivity or specificity of an identified test. [pmid: 9920103].
Yunis J J, Salazar M, Delgado M B, et al. HLA-DQA1, DQB1 and DPB1 alleles on HLA-DQ2- and DQ9-carrying extended haplotypes. Tissue Antigens. 1993;41(1):37-41. Not sensitivity or specificity of an identified test. [pmid: 8096094].
Zaccari G, Mazzetti di, Pietralata Paone F M, et al. A proposal for coeliac disease screening of all infants at the age of fifteen months. Gastroenterol Int. 1996;9(1):11-15. Not sensitivity or specificity of an identified test.
Zacchi Paola, Sblattero Daniele, Florian Fiorella, et al. Selecting open reading frames from DNA. Genome Research. 2003;13(5):980-990. Not sensitivity or specificity of an identified test. [pmid: 12727911]. [pmcid: 430925].
Zachor D A, Mroczek-Musulman E, Brown P. Prevalence of celiac disease in Down syndrome in the United States. Journal of Pediatric Gastroenterology and Nutrition. 2000;31(3):275-279. Not sensitivity or specificity of an identified test. [pmid: 10997372].
Zaitoun A, Record C O. Morphometric studies in duodenal biopsies from patients with coeliac disease: the effect of the steroid fluticasone propionate. Alimentary Pharmacology & Therapeutics. 1991;5(2):151-160. Not sensitivity or specificity of an identified test. [pmid: 1793782].
Zauli D, Grassi A, Granito A, et al. Prevalence of silent coeliac disease in atopics. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2000;32(9):775-779. Not sensitivity or specificity of an identified test. [pmid: 11215557].
Zeeuwen P L J M, Vlijmen-Willems I M J J, Egami H, et al. Cystatin M / E expression in inflammatory and neoplastic skin disorders. British Journal of Dermatology. 2002;147(1):87-94. Not sensitivity or specificity of an identified test. [pmid: 12100189].
Zeeuwen P L J M, Vlijmen-Willems I M J J, Jansen B J H, et al. Cystatin M/E expression is restricted to differentiated epidermal keratinocytes and sweat glands: A new skin-specific proteinase inhibitor that is a target for cross-linking by transglutaminase. J Invest Dermatol. 2001;116(5):693-701. Not sensitivity or specificity of an identified test. [pmid: 11348457].
Zeher M, Szegedi G, Csiki Z, et al. Fibrinolysis-resistant fibrin deposits in minor labial salivary glands of patients with Sjogren's syndrome. Clinical Immunology and Immunopathology. 1994;71(2):149-155. Not sensitivity or specificity of an identified test. [pmid: 7514111].
Zelger B, Weinlich G, Zelger B. Perineuroma. A frequently unrecognized entity with emphasis on a plexiform variant. Advances in Clinical Pathology - the Official Journal of Adriatic Society of Pathology. 2000;4(1):25-33. Not sensitivity or specificity of an identified test. [pmid: 10936896].
Zemaitaitis M O, Lee J M, Troncoso J C, et al. Transglutaminase-induced cross-linking of tau proteins in progressive supranuclear palsy. Journal of Neuropathology and Experimental Neurology. 2000;59(11):983-989. Not sensitivity or specificity of an identified test. [pmid: 11089576].
Zettergren J G, Peterson L L, Wuepper K D. Keratolinin: the soluble substrate of epidermal transglutaminase from human and bovine tissue. Proceedings of the National Academy of Sciences of the United States of America. 1984;81(1):238-242. Not sensitivity or specificity of an identified test. [pmid: 6141559]. [pmcid: 344647].
Zhang H, Koty P P, Mayotte J, et al. Induction of multiple programmed cell death pathways by IFN-beta in human non-small-cell lung cancer cell lines. Experimental Cell Research. 1999;247(1):133-141. Not sensitivity or specificity of an identified test. [pmid: 10047455].
Zhang H, Yousem S A, Franklin W A, et al. Differentiation and programmed cell death-related intermediate biomarkers for the development of non-small cell lung cancer: a pilot study. Human Pathology. 1998;29(9):965-971. Not sensitivity or specificity of an identified test. [pmid: 9744313].
Zhang J, Guttmann R P, Johnson G V. Tissue transglutaminase is an in situ substrate of calpain: regulation of activity. Journal of Neurochemistry. 1998;71(1):240-247. Not sensitivity or specificity of an identified test. [pmid: 9648871].
Zhang J, Lesort M, Guttmann R P, et al. Modulation of the in situ activity of tissue transglutaminase by calcium and GTP. Journal of Biological Chemistry. 1998;273(4):2288-2295. Not sensitivity or specificity of an identified test. [pmid: 9442073].
Zhang J, Tucholski J, Lesort M, et al. Novel bimodal effects of the G-protein tissue transglutaminase on adrenoreceptor signalling. Biochemical Journal. 1999;343(Pt 3):541-549. Not sensitivity or specificity of an identified test. [pmid: 10527931]. [pmcid: 1220584].
Zhang L X, Mills K J, Dawson M I, et al. Evidence for the involvement of retinoic acid receptor RAR alpha-dependent signaling pathway in the induction of tissue transglutaminase and apoptosis by retinoids. Journal of Biological Chemistry. 1995;270(11):6022-6029. Not sensitivity or specificity of an identified test. [pmid: 7890733].
Zhang Rulin, Tremblay Tammy, McDermid Angela, et al. Identification of differentially expressed proteins in human glioblastoma cell lines and tumors. Glia. 2003;42(2):194-208. Not sensitivity or specificity of an identified test. [pmid: 12655603].
Zhang W, Johnson B R, Bjornsson T D. Pharmacologic inhibition of transglutaminase-induced cross-linking of Alzheimer's amyloid beta-peptide. Life Sciences. 1997;60(25):2323-2332. Not sensitivity or specificity of an identified test. [pmid: 9194688].
Zhang W, Johnson B R, Suri D E, et al. Immunohistochemical demonstration of tissue transglutaminase in amyloid plaques. Acta Neuropathologica. 1998;96(4):395-400. Not sensitivity or specificity of an identified test. [pmid: 9797004].
Zhong F, McCombs C C, Olson J M, et al. An autosomal screen for genes that predispose to celiac disease in the western counties of Ireland. Nature Genetics. 1996;14(3):329-333. Not sensitivity or specificity of an identified test. [pmid: 8896565].
Zhu T H, Bodem J, Keppel E, et al. A single ancestral gene of the human LIM domain oncogene family LMO in Drosophila: characterization of the Drosophila Dlmo gene. Oncogene. 1995;11(7):1283-1290. Not sensitivity or specificity of an identified test. [pmid: 7478548].
Zhu Y, Tassi L, Lane W, et al. Specific binding of the transglutaminase, platelet factor XIII, to HSP27. Journal of Biological Chemistry. 1994;269(35):22379-22384. Not sensitivity or specificity of an identified test. [pmid: 7915282].
Ziegler Anette, Schmid Sandra, Huber Doris, et al. Early infant feeding and risk of developing type 1 diabetes-associated autoantibodies. Jama - the Journal of the American Medical Association. 2003;290(13):1721-1728. Not sensitivity or specificity of an identified test. [pmid: 14519706].
Zimmer K P, Naim H, Weber P, et al. Targeting of gliadin peptides, CD8, alpha/beta-TCR, and gamma/delta-TCR to Golgi complexes and vacuoles within celiac disease enterocytes. Faseb Journal - Official Publication of the Federation of American Societies for Experimental Biology. 1998;12(13):1349-1357. Not sensitivity or specificity of an identified test.
Zimmer K P, Poremba C, Weber P, et al. Translocation of gliadin into HLA-DR antigen containing lysosomes in coeliac disease enterocytes. Gut. 1995;36(5):703-709. Not sensitivity or specificity of an identified test. [pmid: 7797120]. [pmcid: 1382673].
Zins B J, Tremaine W J, Carpenter H A. Collagenous colitis: mucosal biopsies and association with fecal leukocytes. Mayo Clinic Proceedings. 1995;70(5):430-433. Not sensitivity or specificity of an identified test. [pmid: 7731251].
Zipser R D, Patel S, Yahya K Z, et al. Presentations of adult celiac disease in a nationwide patient support group. Digestive Diseases and Sciences. 2003;48(4):761-764. Not sensitivity or specificity of an identified test. [pmid: 12741468].
Zubillaga P, Vitoria J C, Arrieta A, et al. Down Syndrome and celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 1993;16(2):168-171. Not sensitivity or specificity of an identified test. [pmid: 8450384].
Zubillaga Paul, Vidales Maria, Concepcion Zubillaga, et al. HLA-DQA1 and HLA-DQB1 genetic markers and clinical presentation in celiac disease. Journal of Pediatric Gastroenterology and Nutrition. 2002;34(5):548-554. Improper control group. [pmid: 12050583].
Zuin G, Fontana M, Morelli A, et al. Antigliadin antibodies in HIV-infected children. Pediatric Aids and Hiv Infection. 1996;7(6):409-412. Not sensitivity or specificity of an identified test. [pmid: 11361497].

### Objective 2 - Prevalence and Incidence of CD

Abdulkarim A S, Murray J A. Review article: The diagnosis of coeliac disease. Aliment Pharmacol Ther. 2003;17(8):987-995. No prevalence or incidence reported. [pmid: 12694080].
Abdullah A M. Aetiology of chronic diarrhoea in children: experience at King Khalid University Hospital, Riyadh, Saudi Arabia. Ann Trop Paediatr. 1994;14(2):111-117. Not a relevant screening geography. [pmid: 7521625].
Abele M, Schols L, Schwartz S, et al. Prevalence of antigliadin antibodies in ataxia patients. Neurology. 2003;60(10):1674-1675. No prevalence or incidence reported. [pmid: 12771263].
Acalovschi M. Coeliac disease and lymphoma. Rom J Gastroenterol. 2001;10(4):317-320. No prevalence or incidence reported.
Addolorato G, Capristo E, Ghittoni G, et al. Anxiety but not depression decreases in coeliac patients after one-year gluten-free diet: a longitudinal study. Scand J Gastroenterol. 2001;36(5):502-506. No prevalence or incidence reported. [pmid: 11346203].
Addolorato G, Stefanini G, Capristo E, et al. Anxiety and depression in adult untreated celiac subjects and in patients affected by inflammatory bowel disease: A personality ‘trait’ or a reactive illness?. Hepatogastroenterology. 1996;43(12):1513-1517. No prevalence or incidence reported. [pmid: 8975957].
Adeniji O A, DiPalma J A. Food allergy. Pract Gastroenterol. 2003;27(4):49-56. No prevalence or incidence reported.
Agardh D, Nilsson A, Carlsson A, et al. Tissue transglutaminase autoantibodies and human leucocyte antigen in Down Syndrome patients with coeliac disease. Acta Paediatr. 2002;91(1):34-38. No prevalence or incidence reported. [pmid: 11883815].
Agrawal S, Gupta A, Yachha S K. Association of human leucocyte-DR and DQ antigens in coeliac disease: a family study. J Gastroenterol Hepatol. 2000;15(7):771-774. No prevalence or incidence reported. [pmid: 10937683].
Agreus L, Svardsudd K, Tibblin G, et al. Endomysium antibodies are superior to gliadin antibodies in screening for coeliac disease in patients presenting supposed functional gastrointestinal symptoms. Scand J Prim Health Care. 2000;18(2):105-110. No prevalence or incidence reported. [pmid: 10944065].
Aguirre J M, Rodriguez R, Oribe D, et al. Dental enamel defects in celiac patients. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 1997;84(6):646-650. No prevalence or incidence reported. [pmid: 9431534].
Ahmed A R, Hameed A. Bullous pemphigoid and dermatitis herpetiformis. Clin Dermatol. 1993;11(1):47-52. No prevalence or incidence reported. [pmid: 8339200].
Aine L, Maki M, Collin P, et al. Dental enamel defects in celiac disease. Journal of Oral Pathology & Medicine - Official Publication of the International Association of Oral Pathologists and the American Academy of Oral Pathology. 1990;19(6):241-245. No prevalence or incidence reported. [pmid: 2401959].
Aine L, Maki M, Reunala T. Coeliac-type dental enamel defects in patients with dermatitis herpetiformis. Acta Derm Venereol. 1992;72(1):25-27. No prevalence or incidence reported. [pmid: 1350136].
Aine L. Coeliac-type permanent-tooth enamel defects. Ann Med. 1996;28(1):9-12. No prevalence or incidence reported. [pmid: 8932499].
Akerblom H K, Knip M. Putative environmental factors in Type 1 diabetes. Diabetes Metab Rev. 1998;14(1):31-67. No prevalence or incidence reported. [pmid: 9679671].
Al Ashwal A A, Shabib S M, Sakati N A. Prevalence and characteristics of celiac disease in type I diabetes mellitus in Saudi Arabia. Saudi Med J. 2003;24(10):1113-1115. No prevalence or incidence reported. [pmid: 14578980].
Al Attas R A. How common is celiac disease in Eastern Saudi Arabia?. Ann Saudi Med. 2002;22(56):315-319. No prevalence or incidence reported. [pmid: 17146251].
Al Bayatti S. Etiology of chronic diarrhea. Saudi Med J. 2002;23(6):675-679. No prevalence or incidence reported. [pmid: 12070546].
Al Mondhiry H. Primary lymphomas of the small intestine: east-west contrast. Am J Hematol. 1986;22(1):89-105. No prevalence or incidence reported. [pmid: 3953568].
al Tawaty A I, Elbargathy S M. Coeliac disease in north-eastern Libya. Ann Trop Paediatr. 1998;18(1):27-30. Not a relevant screening geography. [pmid: 9691998].
Albert E D, Harms K, Wank R, et al. Segregation analysis of HL-A antigens and haplotypes in 50 families of patients with coeliac disease. Transplant Proc. 1973;5(4):1785-1789. No prevalence or incidence reported. [pmid: 4775642].
Alper C A, Awdeh Z L, Yunis E J. Complotypes, extended haplotypes, male segregation distortion, and disease markers. Hum Immunol. 1986;15(4):366-373. No prevalence or incidence reported. [pmid: 3516938].
Alper C A, Fleischnick E, Awdeh Z, et al. Extended major histocompatibility complex haplotypes in patients with gluten-sensitive enteropathy. Eur J Clin Invest. 1987;79(1):251-256. No prevalence or incidence reported.
Alpers D H. The role of nutritional deficiency in the osteopenia and osteoporosis of gastrointestinal diseases. Curr Opin Gastroenterol. 2002;18(2):203-208. No prevalence or incidence reported. [pmid: 17033288].
Altmann D M, Sansom D, Marsh S G. What is the basis for HLA-DQ associations with autoimmune disease?. Immunol Today. 1991;12(8):267-270. No prevalence or incidence reported. [pmid: 1910448].
Altmann D M. HLA-DQ associations with autoimmune disease. Autoimmunity. 1992;14(1):79-83. No prevalence or incidence reported. [pmid: 1299350].
Altuntas B, Kansu A, Ensari A, et al. Celiac disease in Turkish short-statured children and the value of antigliadin antibody in diagnosis. Nippon Shonika Gakkai Zasshi. 1998;40(5):457-460. Not a relevant screening geography.
Altuntas cedil, Filik B, Ensari A, et al. Can zinc deficiency be used as a marker for the diagnosis of celiac disease in Turkish children with short stature?. Pediatr Int. 2000;42(6):682-684. No prevalence or incidence reported. [pmid: 11192528].
Alvarez D, Vazquez H, Bai J C. Superior mesenteric artery blood flow in celiac disease. Dig Dis Sci. 1993;38(7):1175-1182. No prevalence or incidence reported. [pmid: 8325179].
Amann S T, Bishop M, Curington C, et al. Fecal pancreatic elastase 1 is inaccurate in the diagnosis of chronic pancreatitis. Pancreas. 1996;13(3):226-230. No prevalence or incidence reported. [pmid: 8884841].
Ament M E, Perera D R, Esther L J. Sucrase-isomaltase deficiency-a frequently misdiagnosed disease. Eur J Pediatr. 1973;83(5):721-727. No prevalence or incidence reported.
Amin Rakesh, Murphy Nuala, Edge Julie, et al. A longitudinal study of the effects of a gluten-free diet on glycemic control and weight gain in subjects with type 1 diabetes and celiac disease. Diabetes Care. 2002;25(7):1117-1122. No prevalence or incidence reported. [pmid: 12087007].
Amirhakimi G H, Samloff I M, Bryson M F, et al. Intestinal lymphangiectasia. Metabolic studies. Am J Dis Child. 1969;117(2):178-185. No prevalence or incidence reported. [pmid: 5763829].
Ammann R W, Hammer B, Fumagalli I. Chronic pancreatitis in Zurich, 1963-1972. Clinical findings and follow-up studies of 102 cases. Digestion. 1973;9(5):404-415. No prevalence or incidence reported. [pmid: 4784702].
Anand A C, Elias E, Neuberger J M. End-stage primary biliary cirrhosis in a first generation migrant south Asian population. Eur J Gastroenterol Hepatol. 1996;8(7):663-666. No prevalence or incidence reported. [pmid: 8853255].
Anderson J A. The clinical spectrum of food allergy in adults. Clin Exp Allergy Suppl. 1991;21(1):304-315. No prevalence or incidence reported.
Anderson R P, Degano P, Godkin A J. In vivo antigen challenge in celiac disease identifies a single transglutaminase-modified peptide as the dominant A-gliadin T-cell epitope. Nat Med. 2000;6(3):337-342. No prevalence or incidence reported. [pmid: 10700238].
Andersson-Wenckert I, Blomquist H K, Fredrikzon B. Oral health in coeliac disease and cow's milk protein intolerance. Swed Dent J. 1984;8(1):9-14. No prevalence or incidence reported. [pmid: 6585998].
Andre F, Andre C, Colin L, et al. Role of new allergens and of allergens consumption in the increased incidence of food sensitizations in France. Toxicology. 1994;93(1):77-83. No prevalence or incidence reported. [pmid: 7974507].
Annibale B, Capurso G, Delle Fave G. The stomach and iron deficiency anaemia: a forgotten link. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2003;35(4):288-295. No prevalence or incidence reported. [pmid: 14703882].
Annibale B, Severi C, Chistolini A, et al. Efficacy of gluten-free diet alone on recovery from iron deficiency anemia in adult celiac patients. Am J Gastroenterol. 2001;96(1):132-137. No prevalence or incidence reported. [pmid: 11197242].
Anonymous. A guide for patients. Pract Gastroenterol 2002;26(11):58–61. No prevalence or incidence reported
Anonymous. A long-term survey of coeliac disease. Med J Aust 1971;2(20):992 No prevalence or incidence reported
Anonymous. American Gastroenterological Association medical position statement: Celiac Sprue. Gastroenterology 2001;120(6):1522–1525. No prevalence or incidence reported
Anonymous. American Gastroenterological Association medical position statement: guidelines on osteoporosis in gastrointestinal diseases. Gastroenterology 2003;124(3):791–794. No prevalence or incidence reported
Anonymous. American Thoracic Society/European Respiratory Society statement: Standards for the diagnosis and management of individuals with alpha-1 antitrypsin deficiency. Am J Respir Crit Care Med 2003;168(7):818–900. No prevalence or incidence reported
Anonymous. Are your GI symptoms linked to wheat?. Johns Hopkins Med Lett Health After 50 2003;15(5):3, 7No prevalence or incidence reported
Anonymous. Catch-up growth in celiac disease. Nutr Rev 1973;31(1):13–14. No prevalence or incidence reported
Anonymous. Celiac disease and how to live with it. Harvard Women's Health Watch 2001;8(9):3–4. No prevalence or incidence reported
Anonymous. Celiac disease. Am Fam Phys 1998;57(5):1039–1041. No prevalence or incidence reported
Anonymous. Coeliac disease in the West of Ireland. Br Med J 1973;2(5864):484–485. No prevalence or incidence reported
Anonymous. Coeliac disease. Br Med J 1970;4(726):1–2. No prevalence or incidence reported
Anonymous. Editorial: Drop-outs' diarrhoea. Br Med J 1974;3(5927):373 No prevalence or incidence reported
Anonymous. Giardia lamblia and coeliac disease. Lancet 1973;2(7821):138 No prevalence or incidence reported
Anonymous. Highly inheritable coeliac disease. Med Today 2002;3(7):15No prevalence or incidence reported
Anonymous. Hypophosphataemic osteomalacia in adults. Lancet 1971;1(7713):1343 No prevalence or incidence reported
Anonymous. Irritable bowel syndrome. Merec Bull 2000;11(11):41–44. No prevalence or incidence reported
Anonymous. M2A(R) capsule endoscopy common diseases & current data: Including results from Digestive Disease Week (DDW) 2002, San Francisco, May 19th–22nd. Endoscopy 2002;34(7):I-V. No prevalence or incidence reported
Anonymous. Minerva. Br Med J 1996;312(7040):1238. No prevalence or incidence reported
Anonymous. Patient support organisations: The coeliac society of Australia. Aust Prescr 2001;24(2):40No prevalence or incidence reported
Anonymous. RCN Paediatric and Adolescent Diabetes Group 2002 Conference. Pract Diabetes Int 2003;20(2):77No prevalence or incidence reported
Anonymous. Sedondary effects of iron deficiency. Nutr Rev 1969;27(2):41–43. No prevalence or incidence reported
Anonymous. Summary and recommendations: Classification of gastrointestinal manifestations due to immunologic reactions to foods in infants and young children. J Pediatr Gastroenterol Nutr 2000;30(Suppl 1):S87–S94. No prevalence or incidence reported
Anonymous. Thyroid disease in young diabetics. Lancet 1982;1(8284):1285–1286. No prevalence or incidence reported
Anonymous. What you need to know about … coeliac disease. Nurs Times 2003;99(10):30No prevalence or incidence reported
Ansaldi-Balocco N, Santini B, Sarchi C. Efficacy of pancreatic enzyme supplementation in children with cystic fibrosis: comparison of two preparations by random crossover study and a retrospective study of the same patients at two different ages. J Pediatr Gastroenterol Nutr. 1988;7(Suppl 1):s40-s45. No prevalence or incidence reported. [pmid: 3042938].
Anson O, Weizman Z, Zeevi N. Celiac disease: parental knowledge and attitudes of dietary compliance. Pediatrics. 1990;85(1):98-103. No prevalence or incidence reported. [pmid: 2296499].
Anton H C. Thinning of the clavicular cortex in adults under the age of 45 in osteomalacia and hyperparathyroidism. Clin Radiol. 1979;30(3):307-310. No prevalence or incidence reported. [pmid: 455904].
Arato A, Savilahti E, Tainio V M, et al. HLA-DR expression, natural killer cells and IgE containing cells in the jejunal mucosa of coeliac children. Gut. 1987;28(8):988-994. No prevalence or incidence reported. [pmid: 3311907]. [pmcid: 1433137].
Araya M, Henderson-Smart D. Letter: Coeliac disease: an undiagnosed disorder with important implications. Med J Aust. 1974;1(14):549. No prevalence or incidence reported. [pmid: 4831751].
Araya M, Mondragon A, Perez-Bravo F, et al. Celiac disease in a Chilean population carrying Amerindian traits. J Pediatr Gastroenterol Nutr. 2000;31(4):381-386. No prevalence or incidence reported. [pmid: 11045834].
Arden Nigel K, Cooper Cyrus. Assessment of the risk of fracture in patients with gastrointestinal disease. Eur J Gastroenterol Hepatol. 2003;15(8):865-868. No prevalence or incidence reported. [pmid: 12867795].
Armentia A, Martin-Santos J M, Quintero A, et al. Bakers' asthma: prevalence and evaluation of immunotherapy with a wheat flour extract. Ann Allergy. 1990;65(4):265-272. No prevalence or incidence reported. [pmid: 2221484].
Armentia A, Tapias J, Barber D, et al. Sensitization to the storage mite Lepidoglyphus destructor in wheat flour respiratory allergy. Ann Allergy. 1992;68(5):398-403. No prevalence or incidence reported. [pmid: 1586004].
Armes J, Gee D C, Macrae F A. Collagenous colitis: jejunal and colorectal pathology. J Clin Pathol. 1992;45(9):784-787. No prevalence or incidence reported. [pmid: 1401208]. [pmcid: 495104].
Arnala I, Kemppainen T, Kroger H, et al. Bone histomorphometry in celiac disease. Ann Chir Gynaecol. 2001;90(2):100-104. No prevalence or incidence reported. [pmid: 11459257].
Arnason J A, Gudjonsson H, Freysdottir J, et al. Do adults with high gliadin antibody concentrations have subclinical gluten intolerance?. Gut. 1992;33(2):194-197. No prevalence or incidence reported. [pmid: 1541415]. [pmcid: 1373929].
Arnott I D, McDonald D, Williams A, et al. Clinical use of Infliximab in Crohn's disease: the Edinburgh experience. Aliment Pharmacol Ther. 2001;15(10):1639-1646. No prevalence or incidence reported. [pmid: 11564005].
Arranz E, Ferguson A. Intestinal antibody pattern of celiac disease: occurrence in patients with normal jejunal biopsy histology. Gastroenterology. 1993;104(5):1263-1272. No prevalence or incidence reported. [pmid: 8482440].
Arranz E, Telleria J J, Sanz A, et al. HLA-DQA1*0501 and DQB1*02 homozygosity and disease susceptibility in Spanish coeliac patients. Exp Clin Immunogenet. 1997;14(4):286-290. No prevalence or incidence reported. [pmid: 9523165].
Arshad S H, Matthews S, Gant C, et al. Effect of allergen avoidance on development of allergic disorders in infancy. Lancet. 1992;339(8808):1493-1497. No prevalence or incidence reported. [pmid: 1351183].
Arshad S. Food allergen avoidance in primary prevention of food allergy. Allergy Eur J Allergy Clin Immunol Suppl. 2001;56(67):113-116. No prevalence or incidence reported.
Ascher H, Hahn-Zoric M, Hanson L A. Value of serologic markers for clinical diagnosis and population studies of coeliac disease. Scand J Gastroenterol. 1996;31(1):61-67. No prevalence or incidence reported. [pmid: 8927942].
Ascher H, Holm K, Kristiansson B, et al. Different features of coeliac disease in two neighbouring countries. Arch Dis Child. 1993;69(3):375-380. No prevalence or incidence reported. [pmid: 8215549].
Ascher H, Krantz I, Kristiansson B. Increasing incidence of coeliac disease in Sweden. Arch Dis Child. 1991;66(5):608-611. Serology screen <1990. [pmid: 2039251].
Ascher H, Krantz I, Rydberg L, et al. Influence of infant feeding and gluten intake on coeliac disease. Arch Dis Child. 1997;76(2):113-117. Not a relevant screening test. [pmid: 9068298].
Ascher H, Kristiansson B. The highest incidence of celiac disease in Europe: the Swedish experience. J Pediatr Gastroenterol Nutr. 1997;24(5):S3-S6. No prevalence or incidence reported. [pmid: 9161966].
Ascher H. Coeliac disease and type 1 diabetes: an affair still with much hidden behind the veil. Acta Paediatr. 2001;90(11):1217-1220. No prevalence or incidence reported. [pmid: 11808887].
Ascher H. Paediatric aspects of coeliac disease: old challenges and new ones…. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(3):216-224. No prevalence or incidence reported. [pmid: 11990395].
Ashabani A, Errabtea H, Shapan A, et al. Serologic markers of untreated celiac disease in Libyan children: antigliadin, antitransglutaminase, antiendomysial, and anticalreticulin antibodies. J Pediatr Gastroenterol Nutr. 2001;33(3):276-282. No prevalence or incidence reported. [pmid: 11593122].
Ashabani Abdelhakim, Abushofa Umaima, Abusrewill Suliman, et al. The prevalence of coeliac disease in Libyan children with type 1 diabetes mellitus. Diabetes Metab Res Rev. 2003;19(1):69-75. Not a relevant screening geography. [pmid: 12592646].
Ashkenazi A, Cooper M, Nissim F, et al. Occurrence of celiac disease in children in a defined area of Israel. Isr J Med Sci. 1983;19(1):63-66. Not a relevant screening geography. [pmid: 6832950].
Ashorn M. Gastrointestinal diseases in the paediatric age groups in Europe: Epidemiology and impact on healthcare. Aliment Pharmacol Ther Suppl. 2003;18(3):80-83. No prevalence or incidence reported.
Askling Johan, Linet Martha, Gridley Gloria, et al. Cancer incidence in a population-based cohort of individuals hospitalized with celiac disease or dermatitis herpetiformis. Gastroenterology. 2002;123(5):1428-1435. No prevalence or incidence reported. [pmid: 12404215].
Asquith P. Adult coeliac disease and malignancy. Ir Med J. 1974;67(15):417-420. No prevalence or incidence reported. [pmid: 4411887].
Aukee S, Jussila J, Saikku L A. The functional state of the gastrointestinal tract before and after selective surgery. Scand J Gastroenterol. 1969;4(3):241-248. No prevalence or incidence reported. [pmid: 5346671].
Auricchio S, Buffolano W, Ciccimarra F, et al. In vitro proliferation of lymphocytes from celiac children and their first-degree relatives in response to wheat gliadin-derived peptides. J Pediatr Gastroenterol Nutr. 1982;1(4):515-524. No prevalence or incidence reported. [pmid: 7186066].
Auricchio S, Follo D, de Ritis G, et al. Does breast feeding protect against the development of clinical symptoms of celiac disease in children?. J Pediatr Gastroenterol Nutr. 1983;2(3):428-433. No prevalence or incidence reported. [pmid: 6620050].
Auricchio S, Greco L, Troncone R. Gluten-sensitive enteropathy in childhood. Pediatr Clin North Am. 1988;35(1):157-187. No prevalence or incidence reported. [pmid: 3277130].
Auricchio S, Greco L, Troncone R. What is the true prevalence of coeliac disease?. Gastroenterol Int. 1990;3(3):140-142. Review article.
Auricchio S, Mazzacca G, Tosi R, et al. Coeliac disease as a familial condition: Identification of asymptomatic coeliac patients within family groups. Gastroenterol Int. 1988;1(1):25-31. Serology screen <1990.
Austin A S, Logan R F A, Thomason K, et al. Cigarette smoking and adult coeliac disease. Scand J Gastroenterol. 2002;37(8):978-982. No prevalence or incidence reported. [pmid: 12229976].
Axmacher B, Hed J, Ottoson E, et al. Celiac disease and organic dust toxic syndrome. Am J Ind Med. 1990;17(1):94-95. No prevalence or incidence reported. [pmid: 2305806].
Ayres J G. Classification and management of brittle asthma. Br J Hosp Med. 1997;57(8):387-389. No prevalence or incidence reported. [pmid: 9274664].
Bagdi E, Diss T C, Munson P, et al. Mucosal intra-epithelial lymphocytes in enteropathy-associated T-cell lymphoma, ulcerative jejunitis, and refractory celiac disease constitute a neoplastic population. Blood. 1999;94(1):260-264. No prevalence or incidence reported. [pmid: 10381521].
Bagnasco M, Montagna P, De Alessandri A, et al. IgA antiendomysium antibodies in human umbilical cord sections as a screening test in relatives of patients with celiac disease. Allergy. 1997;52(10):1017-1021. No prevalence or incidence reported. [pmid: 9360755].
Bahia M, Rabello A, Brasileiro Filho G, et al. Serum antigliadin antibody levels as a screening criterion before jejunal biopsy indication for celiac disease in a developing country. Brazilian Journal of Medical and Biological Research = Revista Brasileira De Pesquisas Medicas E Biologicas / Sociedade Brasileira De Biofisica …Et Al. 2001;34(11):1415-1420. No prevalence or incidence reported. [pmid: 11668350].
Bahna S L, Tateno K, Heiner D C. Elevated IgD antibodies to wheat in celiac disease. Ann Allergy. 1980;44(3):146-151. No prevalence or incidence reported. [pmid: 7362093].
Bai J C, Andrush A, Matelo G, et al. Fecal fat concentration in the differential diagnosis of steatorrhea. Am J Gastroenterol. 1989;84(1):27-30. No prevalence or incidence reported. [pmid: 2912027].
Bai J C, Maurino E, Martinez C, et al. Abnormal colonic transit time in untreated celiac sprue. Acta Gastroenterol Latinoam. 1995;25(5):277-284. No prevalence or incidence reported. [pmid: 8733253].
Bai J C. Malabsorption syndromes. Digestion. 1998;59(5):530-546. No prevalence or incidence reported. [pmid: 9705537].
Bai J, Moran C, Martinez C, et al. Celiac sprue after surgery of the upper gastrointestinal tract. Report of 10 patients with special attention to diagnosis, clinical behavior, and follow-up. J Clin Gastroenterol. 1991;13(5):521-524. No prevalence or incidence reported. [pmid: 1744387].
Baird I M, Walters R L, Sutton D R. Absorption of slow-release iron and effects of ascorbic acid in normal subjects and after partial gastrectomy. Br Med J. 1974;4(5943):505-508. No prevalence or incidence reported. [pmid: 4215536]. [pmcid: 1612625].
Baker J, Sandhu B K. Nutrition, eating and gastrointestinal conditions in adolescence. J R Coll Phys London. 2000;34(2):137-140. No prevalence or incidence reported.
Balakrishnan V. Management of chronic pancreatitis. Tropical Gastroenterology - Official Journal of the Digestive Diseases Foundation. 1986;7(4):141-146. No prevalence or incidence reported. [pmid: 3603679].
Balas A, Vicario J L, Zambrano A, et al. Absolute linkage of celiac disease and dermatitis herpetiformis to HLA-DQ. Tissue Antigens. 1997;50(1):52-56. No prevalence or incidence reported. [pmid: 9243756].
Balducci-Silano P L, Layrisse Z E. HLA-DP and susceptibility to insulin-dependent diabetes mellitus in an ethnically mixed population. Associations with other HLA-alleles. J Autoimmun. 1995;8(3):425-437. No prevalence or incidence reported. [pmid: 7576003].
Banerji N K, Hurwitz L J. Nervous system manifestations after gastric surgery. Acta Neurol Scand. 1971;47(4):485-513. No prevalence or incidence reported. [pmid: 5123488].
Bansi D S, Chapman R W, Fleming K A. Prevalence and diagnostic role of antineutrophil cytoplasmic antibodies in inflammatory bowel disease. Eur J Gastroenterol Hepatol. 1996;8(9):881-885. No prevalence or incidence reported. [pmid: 8889455].
Bansi D S, Fleming K A, Chapman R W. Importance of antineutrophil cytoplasmic antibodies in primary sclerosing cholangitis and ulcerative colitis: prevalence, titre, and IgG subclass. Gut. 1996;38(3):384-389. No prevalence or incidence reported. [pmid: 8675091]. [pmcid: 1383067].
Banwell J G, Hutt M R, Leonard P J, et al. Exocrine pancreatic disease and the malabsorption syndrome in tropical Africa. Gut. 1967;8(4):388-401. No prevalence or incidence reported. [pmid: 6039729]. [pmcid: 1552548].
Banwell J G, Marsden P D, Blackman V, et al. Hookworm infection and intestinal absorption amongst Africans in Uganda. Am J Trop Med Hyg. 1967;16(3):304-308. No prevalence or incidence reported. [pmid: 6023687].
Barakat M H, Ali S M, Badawi A R, et al. Peroral endoscopic duodenal biopsy in infants and children. Acta Paediatr Scand. 1983;72(4):563-569. No prevalence or incidence reported. [pmid: 6624433].
Barbato M, Miglietta M R, Viola F, et al. Impact of modification of diagnostic techniques and criteria on the presentation of celiac disease in the last 16 years. Observation in Rome. Minerva Pediatr. 1996;48(9):359-363. No prevalence or incidence reported. [pmid: 8968150].
Bardella M T, Fraquelli M, Quatrini M, et al. Prevalence of hypertransaminasemia in adult celiac patients and effect of gluten-free diet. Hepatology. 1995;22(3):833-836. No prevalence or incidence reported. [pmid: 7657290].
Bardella M T, Fredella C, Prampolini L, et al. Body composition and dietary intakes in adult celiac disease patients consuming a strict gluten-free diet. Am J Clin Nutr. 2000;72(4):937-939. No prevalence or incidence reported. [pmid: 11010934].
Bardella M T, Fredella C, Prampolini L, et al. Gluten sensitivity in monozygous twins: A long-term follow-up of five pairs. Am J Gastroenterol. 2000;95(6):1503-1505. No prevalence or incidence reported. [pmid: 10894587].
Bardella M T, Minoli G, Radaelli F, et al. Reevaluation of duodenal endoscopic markers in the diagnosis of celiac disease. Gastroenterol Int. 2000;51(6):714-716. No prevalence or incidence reported.
Bardella M T, Minoli G, Ravizza D, et al. Increased prevalence of celiac disease in patients with dyspepsia. Arch Intern Med. 2000;160(10):1489-1491. Not a relevant screening group. [pmid: 10826463].
Bardella M T, Molteni N, Prampolini L, et al. Need for follow up in coeliac disease. Arch Dis Child. 1994;70(3):211-213. No prevalence or incidence reported. [pmid: 8135565].
Bardella M T, Molteni N, Quatrini M, et al. Clinical, biochemical and histological abnormalities in adult celiac patients on gluten-free diet. Gastroenterol Clin Biol. 1985;9(11):787-789. No prevalence or incidence reported. [pmid: 4085741].
Bardella M T, Vecchi M, Conte D, et al. Chronic unexplained hypertransaminasemia may be caused by occult celiac disease. Hepatology. 1999;29(3):654-657. Not a relevant screening group. [pmid: 10051464].
Barera G, Mora S, Brambilla P, et al. Body composition in children with celiac disease and the effects of a gluten-free diet: a prospective case-control study. Am J Clin Nutr. 2000;72(1):71-75. No prevalence or incidence reported. [pmid: 10871563].
Barlow J M, Johnson C D, Stephens D H. Celiac disease: how common is jejunoileal fold pattern reversal found at small-bowel follow-through?. Ajr. American Journal of Roentgenology. 1996;166(3):575-577. No prevalence or incidence reported. [pmid: 8623630].
Baroncelli G I, Federico G, Bertelloni S, et al. Assessment of bone quality by quantitative ultrasound of proximal phalanges of the hand and fracture rate in children and adolescents with bone and mineral disorders. Pediatr Res. 2003;54(1):125-136. No prevalence or incidence reported. [pmid: 12700367].
Barr G D, Grehan M J. Coeliac disease. Med J Aust. 1998;169(2):109-114. No prevalence or incidence reported. [pmid: 9700349].
Barr G, Cameron D, King S, et al. Current status and management of coeliac disease. Med Today. 2003;4(6):30-39. No prevalence or incidence reported.
Barry R E, Baker P, Read A E. Coeliac disease. The clinical presentation. Clin Gastroenterol. 1974;3(1):55-69. No prevalence or incidence reported. [pmid: 4525532].
Barry R E, Morris J S, Kenwright S, et al. Coeliac disease and malignancy. The possible importance of familial involvement. Scand J Gastroenterol. 1971;6(3):205-207. No prevalence or incidence reported. [pmid: 4254382].
Barta L, Kosnai I, Molnar M, et al. Simultaneous occurrence of diabetes mellitus and coeliac disease. Acta Paediatr Hung. 1985;26(4):303-306. No prevalence or incidence reported. [pmid: 3879451].
Barton D M, Baskar V, Kamalakannan D, et al. An assessment of care of paediatric and adolescent patients with diabetes in a large district general hospital. Diabetic Medicine - a Journal of the British Diabetic Association. 2003;20(5):394-398. No prevalence or incidence reported. [pmid: 12752489].
Bateson M C, Hopwood D, MacGillivray J B. Jejunal morphology in multiple sclerosis. Lancet. 1979;1(8126):1108-1110. No prevalence or incidence reported. [pmid: 86833].
Beaumont D M, Mian M S. Coeliac disease in old age: ‘A catch in the rye’. Age Ageing. 1998;27(4):535-538. No prevalence or incidence reported. [pmid: 9884015].
Becker C. Clinical evaluation for osteoporosis. Clin Geriatr Med. 2003;19(2):299-320. No prevalence or incidence reported. [pmid: 12916288].
Beckett C G, Ciclitira P J. Celiac disase. Curr Opin Gastroenterol. 1997;13(2):107-111. No prevalence or incidence reported.
Beckett C. A gut issue. Nurs Times 1999;95(8):65–6,69. No prevalence or incidence reported
Behne D. Selenium. Ann Nestle. 1994;52(3):107-117. No prevalence or incidence reported.
Bell I R, Schwartz G E, Peterson J M, et al. Possible time-dependent sensitization to xenobiotics: self-reported illness from chemical odors, foods, and opiate drugs in an older adult population. Arch Environ Health. 1993;48(5):315-327. No prevalence or incidence reported. [pmid: 8215596].
Bell I R, Schwartz G E, Peterson J M, et al. Symptom and personality profiles of young adults from a college student population with self-reported illness from foods and chemicals. J Am Coll Nutr. 1993;12(6):693-702. No prevalence or incidence reported. [pmid: 8294725].
Bell J I. The major histocompatibility complex and disease. Curr Opin Immunol. 1989;2(1):114-116. No prevalence or incidence reported. [pmid: 2692618].
Bell J, Rassenti L, Smoot S, et al. HLA-DQ beta-chain polymorphism linked to myasthenia gravis. Lancet. 1986;1(8489):1058-1060. No prevalence or incidence reported. [pmid: 2871336].
Bell S, Green P H R, Kagnoff M F. American gastroenterological association medical position statement: Celiac sprue. Gastroenterology. 2001;120(6):1522-1525. No prevalence or incidence reported. [pmid: 11313323].
Belloni Cesare, Avanzini Maria A, De Silvestri, et al. No evidence of autoimmunity in 6-year-old children immunized at birth with recombinant hepatitis B vaccine. Pediatrics. 2002;110(1 Pt 1):E4. No prevalence or incidence reported. [pmid: 12093985].
Berg N O, Lindberg T. Incidence of coeliac disease and transient gluten intolerance in children in a Swedish urban community. Acta Paediatr Scand. 1979;68(3):397-400. Not a relevant screening geography. [pmid: 575016].
Bernardini R, Novembre E, Ingargiola A, et al. Prevalence and risk factors of latex sensitization in an unselected pediatric population. J Allergy Clin Immunol. 1998;101(5):621-625. No prevalence or incidence reported. [pmid: 9600498].
Bernstein Charles N, Leslie William D, Leboff Meryl S. AGA technical review on osteoporosis in gastrointestinal diseases. Gastroenterology. 2003;124(3):795-841. No prevalence or incidence reported. [pmid: 12612917].
Bernstein Charles N, Leslie William D. The pathophysiology of bone disease in gastrointestinal disease. Eur J Gastroenterol Hepatol. 2003;15(8):857-864. No prevalence or incidence reported. [pmid: 14624148].
Berrill W T, Eade O E, Fitzpatrick P F. Bird Fancier's lung and jejunal villous atrophy. Lancet. 1975;2(7943):1006-1008. No prevalence or incidence reported. [pmid: 53495].
Berti I, Trevisiol C, Tommasini A, et al. Usefulness of screening program for celiac disease in autoimmune thyroiditis. Dig Dis Sci. 2000;45(2):403-406. No prevalence or incidence reported. [pmid: 10711459].
Betuel H, Gebuhrer L, Descos L, et al. Adult celiac disease associated with HLA-DRw3 and -DRw7. Tissue Antigens. 1980;15(3):231-238. No prevalence or incidence reported. [pmid: 6936866].
Bevan S, Popat S, Braegger C P. Contribution of the MHC region to the familial risk of coeliac disease. J Med Genet. 1999;36(9):687-690. No prevalence or incidence reported. [pmid: 10507725].
Bevan S, Popat S, Houlston R S. Relative power of linkage and transmission disequilibrium test strategies to detect non-HLA linked coeliac disease susceptibility genes. Gut. 1999;45(5):668-671. No prevalence or incidence reported. [pmid: 10517901]. [pmcid: 1727705].
Bhatnagar S, Bhan M K. Serological diagnosis of celiac disease. Indian J Pediatr. 1999;66(1 Suppl):S26-S31. No prevalence or incidence reported. [pmid: 11132465].
Biagi F, Corazza G R. Gene and gliadin/gut and kidney. Am J Gastroenterol. 2002;97(10):2486-2488. No prevalence or incidence reported. [pmid: 12385427].
Biagi F, Corazza G R. Tissue transglutaminase antibodies: Is sensitivity more important than specificity?. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2001;33(5):401-402. No prevalence or incidence reported. [pmid: 11785714].
Biagi F, Ellis H J, Parnell N D, et al. A non-toxic analogue of a coeliac-activating gliadin peptide: a basis for immunomodulation?. Aliment Pharmacol Ther. 1999;13(7):945-950. No prevalence or incidence reported. [pmid: 10383530].
Bianchi M L, Bardella M T. Bone and celiac disease. Calcif Tissue Int. 2002;71(6):465-471. No prevalence or incidence reported. [pmid: 12232681].
Biemond I, Pena A S, Groenland F, et al. Coeliac disease in The Netherlands: demographic data of a patient survey among the members of the Dutch Coeliac Society. Neth J Med. 1987;31(56):263-268. No prevalence or incidence reported. [pmid: 3431619].
Bilbao J R, Martin-Pagola A, Vitoria J C, et al. HLA-DRB1 and MHC class 1 chain-related A haplotypes in Basque families with celiac disease. Tissue Antigens. 2002;60(1):71-76. No prevalence or incidence reported. [pmid: 12366785].
Bilbao J, Ramon Vitoria, Juan C, et al. Immunoglobulin G autoantibodies against tissue-transglutaminase. A sensitive, cost-effective assay for the screening of celiac disease. Autoimmunity. 2002;35(4):255-259. No prevalence or incidence reported. [pmid: 12482193].
Bini E J. Helicobacter pylori and iron deficiency anemia: Guilty as charged?. Am J Med. 2001;111(6):495-497. No prevalence or incidence reported. [pmid: 11690578].
Birkbeck J A. Coeliac disease in a diabetic child. Lancet. 1969;2(7618):496. No prevalence or incidence reported. [pmid: 4183926].
Bischoff S C, Mayer J H, Manns M P. Allergy and the gut. Int Arch Allergy Immunol. 2000;121(4):270-283. No prevalence or incidence reported. [pmid: 10828717].
Bischoff S C, Mayer J, Wedemeyer J, et al. Colonoscopic allergen provocation (COLAP): a new diagnostic approach for gastrointestinal food allergy. Gut. 1997;40(6):745-753. No prevalence or incidence reported. [pmid: 9245928]. [pmcid: 1027199].
Bischoff S C. Mucosal allergy: role of mast cells and eosinophil granulocytes in the gut. Bailliere's Clinical Gastroenterology. 1996;10(3):443-459. No prevalence or incidence reported. [pmid: 8905118].
Bizzaro N, Villalta D, Tonutti E, et al. Association of celiac disease with connective tissue diseases and autoimmune diseases of the digestive tract. Autoimmun Rev. 2003;2(6):358-363. No prevalence or incidence reported. [pmid: 14550877].
Bjorksten B. Allergy priming early in life. Lancet. 1999;353(9148):167-168. No prevalence or incidence reported. [pmid: 9923869].
Bjorksten B. The role of the gastrointestinal tract in the development of respiratory hypersensitivities. Toxicol Lett. 1996;86(23):85-88. No prevalence or incidence reported. [pmid: 8711783].
Bjorksten F, Backman A, Jarvinen K A. Immunoglobulin E specific to wheat and rye flour proteins. Clin Allergy. 1977;7(5):473-483. No prevalence or incidence reported. [pmid: 589781].
Bjornsson E, Janson C, Plaschke P, et al. Prevalence of sensitization to food allergens in adult Swedes. Annals of Allergy, Asthma & Immunology - Official Publication of the American College of Allergy, Asthma, & Immunology. 1996;77(4):327-332. No prevalence or incidence reported. [pmid: 8885811].
Black Corri, Kaye James A, Jick Hershel. Relation of childhood gastrointestinal disorders to autism: nested case-control study using data from the UK General Practice Research Database. BMJ. 2002;325(7361):419-421. No prevalence or incidence reported. [pmid: 12193358]. [pmcid: 119436].
Blanco A, Garrote J A, Alonso M et al. Soluble CD4 antigen is increased in active coeliac disease. Adv Exp Med Biol 1995;371b1355–1358. No prevalence or incidence reported
Blomme B, Gerlo E, Hauser B, et al. Disaccharidase activities in Belgian children: Reference intervals and comparison with non-Belgian Caucasian children. Acta Paediatr Int J Paediatr. 2003;92(7):806-810. No prevalence or incidence reported.
Bode S, Gudmand-Hoyer E. Incidence and clinical significance of lactose malabsorption in adult coeliac disease. Scand J Gastroenterol. 1988;23(4):484-488. No prevalence or incidence reported. [pmid: 3132738].
Bode S, Gudmand-Hoyer E. Symptoms and haematologic features in consecutive adult coeliac patients. Scand J Gastroenterol. 1996;31(1):54-60. No prevalence or incidence reported. [pmid: 8819220].
Bodmer W F. The HLA system and disease. The Oliver Sharpey Lecture 1979. J R Coll Physicians Lond. 1980;14(1):43-50. No prevalence or incidence reported. [pmid: 6777490].
Boehm P, Nassimbeni G, Ventura A. Chronic non-specific diarrhoea in childhood: How often is it iatrogenic?. Acta Paediatr Int J Paediatr. 1998;87(3):268-271. No prevalence or incidence reported.
Boersma B, Houwen R H J, Blum W F, et al. Catch-up growth and endocrine changes in childhood celiac disease. Endocrine changes during catch-up growth. Horm Res. 2002;58(Suppl 1):57-65. No prevalence or incidence reported. [pmid: 12373016].
Bognetti E, Riva M C, Bonfanti R, et al. Growth changes in children and adolescents with short-term diabetes. Diabetes Care. 1998;21(8):1226-1229. No prevalence or incidence reported. [pmid: 9702424].
Bolognesi E, Karell K, Percopo S, et al. Additional factor in some HLA DR3/DQ2 haplotypes confers a fourfold increased genetic risk of celiac disease. Tissue Antigens. 2003;61(4):308-316. No prevalence or incidence reported. [pmid: 12753669].
Bolsover W J, Hall M A, Vaughan R W, et al. A family study confirms that the HLA-DP associations with celiac disease are the result of an extended HLA-DR3 haplotype. Hum Immunol. 1991;31(2):100-108. No prevalence or incidence reported. [pmid: 1676703].
Bonamico M, Ballati G, Mariani P, et al. Screening for coeliac disease: the meaning of low titers of anti-gliadin antibodies (AGA) in non-coeliac children. Eur J Epidemiol. 1997;13(1):55-59. No prevalence or incidence reported. [pmid: 9062780].
Bonamico M, Bottaro G, Pasquino A M, et al. Celiac disease and turner syndrome. J Pediatr Gastroenterol Nutr. 1998;26(5):496-499. No prevalence or incidence reported. [pmid: 9586758].
Bonamico M, Mariani P, Danesi H M, et al. Prevalence and clinical picture of celiac disease in italian down syndrome patients: a multicenter study. J Pediatr Gastroenterol Nutr. 2001;33(2):139-143. Not a relevant screening group. [pmid: 11568513].
Bonamico M, Mariani P, Mazzilli M C, et al. Frequency and clinical pattern of celiac disease among siblings of celiac children. J Pediatr Gastroenterol Nutr. 1996;23(2):159-163. Not a relevant screening group. [pmid: 8856583].
Bonamico M, Mariani P, Mazzilli M C, et al. Frequency and clinical pattern of celiac disease among siblings of celiac children. J Pediatr Gastroenterol Nutr. 1996;23(2):159-163. Not a relevant screening group. [pmid: 8856583].
Bonamico M, Morellini M, Mariani P, et al. HLA antigens and antigliadin antibodies in coeliac disease. Dis Markers. 1991;9(6):313-317. No prevalence or incidence reported. [pmid: 1823310].
Bonamico M, Rasore-Quartino A, Mariani P, et al. Down syndrome and coeliac disease: Usefulness of antigliadin and antiendomysium antibodies. Acta Paediatr Int J Paediatr. 1996;85(12):1503-1505. No prevalence or incidence reported.
Bonamico M, Scire G, Mariani P, et al. Short stature as the primary manifestation of monosymptomatic celiac disease. J Pediatr Gastroenterol Nutr. 1992;14(1):12-16. No prevalence or incidence reported. [pmid: 1573504].
Bonamico M, Vania A, Monti S, et al. Iron deficiency in children with celiac disease. J Pediatr Gastroenterol Nutr. 1987;6(5):702-706. No prevalence or incidence reported. [pmid: 3694363].
Bonamico Margherita, Pasquino Anna M, Mariani Paolo, et al. Prevalence and clinical picture of celiac disease in Turner syndrome. J Clin Endocrinol Metab. 2002;87(12):5495-5498. Not a relevant screening group. [pmid: 12466343].
Bonifacio E, Ziegler A G, Hummel M, et al. Gluten: is it also a determinant of islet autoimmunity?. Diabetes Metab Rev. 1998;14(3):258-259. No prevalence or incidence reported. [pmid: 9816477].
Boniotto Michele, Braida Laura, Spano Andrea, et al. Variant mannose-binding lectin alleles are associated with celiac disease. Immunogenetics. 2002;54(8):596-598. No prevalence or incidence reported. [pmid: 12439623].
Bontems P, Deprettere A, Cadranel S, et al. The coeliac iceberg: a consensus in paediatrics. Acta Gastroenterol Belg. 2000;63(2):157-162. No prevalence or incidence reported. [pmid: 10925451].
Book L, Hart A, Black J, et al. Prevalence and clinical characteristics of celiac disease in Downs syndrome in a US study. Am J Med Genet. 2001;98(1):70-74. Not a relevant screening group. [pmid: 11426458].
Book Linda S. Diagnosing celiac disease in 2002: who, why, and how?. Pediatrics. 2002;109(5):952-954. No prevalence or incidence reported. [pmid: 11986459].
Bottaro G, Cataldo F, Rotolo N, et al. The clinical pattern of subclinical/silent celiac disease: an analysis on 1026 consecutive cases. Am J Gastroenterol. 1999;94(3):691-696. Not a relevant screening group. [pmid: 10086653].
Bottaro G, Failla P, Rotolo N, et al. Changes in coeliac disease behaviour over the years. Acta Paediatr. 1993;82(67):566-568. Not a relevant screening test. [pmid: 8338991].
Boudraa G, Hachelaf W, Benbouabdellah M, et al. Prevalence of coeliac disease in diabetic children and their first- degree relatives in west Algeria: screening with serological markers. Acta Paediatr. 1996;412(Suppl):58-60. Not a relevant screening geography.
Bouguerra F, Babron M C, Eliaou J F, et al. Synergistic effect of two HLA heterodimers in the susceptibility to celiac disease in Tunisia. Genet Epidemiol. 1997;14(4):413-422. No prevalence or incidence reported. [pmid: 9271713].
Bouguerra F, Dugoujon J M, Babron M C, et al. Susceptibility to coeliac disease in Tunisian children and GM immunoglobulin allotypes. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1999;26(4):293-297. No prevalence or incidence reported. [pmid: 10457894].
Bourgain C, Genin E, Holopainen P, et al. Use of closely related affected individuals for the genetic study of complex diseases in founder populations. Am J Hum Genet. 2001;68(1):154-159. No prevalence or incidence reported. [pmid: 11102286]. [pmcid: 1234909].
Bourke M, O'Donovan M, Stevens F M, et al. Alpha 1-antitrypsin phenotypes in coeliac patients and a control population in the west of Ireland. Ir J Med Sci. 1993;162(5):171-172. No prevalence or incidence reported. [pmid: 8335451].
Bourke S, Murphy B, Stafford F, et al. Population differences in intestinal permeability to chromium. EDTA. 1988;157(9):287-289. No prevalence or incidence reported.
Boy M F, La Nasa G, Balestrieri A, et al. Distribution of HLA-DPB1, -DQB1 -DQA1 alleles among Sardinian celiac patients. Dis Markers. 1995;12(3):199-204. No prevalence or incidence reported. [pmid: 8590546].
Boyd S, Collins B J, Bell P M, et al. Clinical presentation of coeliac disease in adult gastroenterological practice. Ulster Med J. 1985;54(2):140-147. No prevalence or incidence reported. [pmid: 4095802].
Brady M S, Rickard K, Yu P L, et al. Effectiveness and safety of small vs. large doses of enteric coated pancreatic enzymes in reducing steatorrhea in children with cystic fibrosis: a prospective randomized study. Pediatr Pulmonol. 1991;10(2):79-85. No prevalence or incidence reported. [pmid: 2030925].
Braegger C P, MacDonald T T. The immunologic basis for celiac disease and related disorders. Semin Gastrointest Dis. 1996;7(3):124-133. No prevalence or incidence reported. [pmid: 8817764].
Braga M, Zerbi A, Dal Cin S, et al. Postoperative management of patients with total exocrine pancreatic insufficiency. Br J Surg. 1990;77(6):669-672. No prevalence or incidence reported. [pmid: 2383737].
Bragelmann R, Armbrecht U, Rosemeyer D, et al. The effect of pancreatic enzyme supplementation in patients with steatorrhoea after total gastrectomy. Eur J Gastroenterol Hepatol. 1999;11(3):231-237. No prevalence or incidence reported. [pmid: 10333193].
Brai M, Accardo P, Bellavia D. Polymorphism of the complement components in human pathology. Annali Italiani Di Medicina Interna - Organo Ufficiale Della Societa Italiana Di Medicina Interna. 1994;9(3):167-172. No prevalence or incidence reported. [pmid: 7946894].
Brandt L J, Locke G R, Olden K, et al. An evidence-based approach to the management of irritable bowel syndrome in North America. Am J Gastroenterol. 2002;97(11 SUPPL.):S1-S26. No prevalence or incidence reported. [pmid: 12425586].
Brandtzaeg P, Baklien K. Characterization of the IgA immunocyte population and its product with excessive intestinal formation of IgA. Clin Exp Immunol. 1977;30(1):77-88. No prevalence or incidence reported. [pmid: 414864]. [pmcid: 1541161].
Branski D, Troncone R. Celiac disease: A reappraisal. Eur J Pediatr. 1998;133(2):181-187. No prevalence or incidence reported.
Brautbar C, Freier S, Ashkenazi A, et al. Histocompatibility determinants in Israeli Jewish patients with coeliac disease: population and family study. Tissue Antigens. 1981;17(3):313-322. No prevalence or incidence reported. [pmid: 6947507].
Brautbar C, Zlotogora J, Laufer N, et al. Do identical HLA-DR3 genes convey susceptibility to celiac disease and insulin dependent diabetes mellitus?. Tissue Antigens. 1984;23(1):58-60. No prevalence or incidence reported. [pmid: 6608164].
Braverman D Z. Gallbladder contraction in patients with irritable bowel syndrome. Isr J Med Sci. 1987;23(3):181-184. No prevalence or incidence reported. [pmid: 3294738].
Brett P M, Yiannakou J Y, Morris M A, et al. A pedigree-based linkage study of coeliac disease: failure to replicate previous positive findings. Ann Hum Genet. 1998;62(Pt 1):25-32. No prevalence or incidence reported. [pmid: 9659975].
Brett P M, Yiannakou J Y, Morris M A, et al. Common HLA alleles, rather than rare mutants, confer susceptibility to coeliac disease. Ann Hum Genet. 1999;63(Pt 3):217-225. No prevalence or incidence reported. [pmid: 10738534].
Brigden M L. A systematic approach to macrocytosis: Sorting out the causes. Postgrad Med 1995;97(5):171–172+175. No prevalence or incidence reported
Brink S J. Pediatric, adolescent, and young-adult nutrition issues in IDDM. Diabetes Care. 1988;11(2):192-200. No prevalence or incidence reported. [pmid: 3289868].
Brocchi E, Tomassetti P, Misitano B, et al. Endoscopic markers in adult coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(3):177-182. No prevalence or incidence reported. [pmid: 11990389].
Brooklyn Trevor N, Di Mambro, Alexandra J, et al. Patients over 45 years with iron deficiency require investigation. Eur J Gastroenterol Hepatol. 2003;15(5):535-538. No prevalence or incidence reported. [pmid: 12702912].
Brown J C, EDITOR S, Matsuo Y et al. The regulation of insulin secretion by gastrointestinal hormones. Gastrointestinal Function Regulation and Disturbances: Proceedings of the Seventh Symposium on the Regulation and Disturbances of Gastrointestinal Function Ic 1989;3–20. No prevalence or incidence reported
Brown M R, Lillibridge C B. When to think of celiac disease: the classical features of gluten sensitive enteropathy are absent. Clin Pediatr (Phila). 1975;14(1):76-82. No prevalence or incidence reported. [pmid: 46189].
Bruno G, Cantani A, Ragno V, et al. Natural history of IgE antibodies in children at risk for atopy. Annals of Allergy, Asthma & Immunology - Official Publication of the American College of Allergy, Asthma, & Immunology. 1995;74(5):431-436. No prevalence or incidence reported. [pmid: 7749975].
Brusco G, Di Stefano M, Corazza G R. Increased red cell distribution width and coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2000;32(2):128-130. No prevalence or incidence reported. [pmid: 10975787].
Brusco G, Izzi L, Corazza G R. Tissue transglutaminase antibodies for coeliac disease screening. Ital J Gastroenterol Hepatol. 1998;30(5):496-497. No prevalence or incidence reported. [pmid: 9836104].
Bryant D A, Mintz E D, Puhr N D, et al. Colonic epithelial lymphocytosis associated with an epidemic of chronic diarrhea. Am J Surg Pathol. 1996;20(9):1102-1109. No prevalence or incidence reported. [pmid: 8764747].
Budiarso A, Sunoto S, Hendardji H, et al. Incidence of steatorrhoea in Indonesian infants. Paediatr Indones. 1977;17(12):6-9. No prevalence or incidence reported. [pmid: 876665].
Burgin-Wolff A, Bertele R M, Berger R, et al. A reliable screening test for childhood celiac disease: fluorescent immunosorbent test for gliadin antibodies. A prospective multicenter study. Eur J Pediatr. 1983;102(5):655-660. No prevalence or incidence reported.
Burgin-Wolff A, Dahlbom I, Hadziselimovic F, et al. Antibodies against human tissue transglutaminase and endomysium in diagnosing and monitoring coeliac disease. Scand J Gastroenterol. 2002;37(6):685-691. No prevalence or incidence reported. [pmid: 12126247].
Burks A W, Sampson H. Food allergies in children. Curr Probl Pediatr. 1993;23(6):230-252. No prevalence or incidence reported. [pmid: 8404010].
Burrows R, Leiva L, Burgueno M, et al. Bone mineral density (BMD) in children with celiac disease (CD): Its relation to puberty and calcium intake. Nutr Res. 1999;19(4):493-499. No prevalence or incidence reported.
Bushara K O, Goebel S U, Shill H, et al. Gluten sensitivity in sporadic and hereditary cerebellar ataxia. Ann Neurol. 2001;49(4):540-543. No prevalence or incidence reported. [pmid: 11310636].
Businco L, Ziruolo M G, Ferrara M, et al. Natural history of atopic dermatitis in childhood: an updated review and personal experience of a five-year follow-up. Allergy. 1989;44(Suppl 9):70-78. No prevalence or incidence reported. [pmid: 2683845].
Buts J P, Morin C L, Roy C C, et al. One-hour blood xylose test: a reliable index of small bowel function. Eur J Pediatr. 1978;92(5):729-733. No prevalence or incidence reported.
Butterworth Jeffrey R, Cooper Brian T, Rosenberg William M C, et al. The role of hemochromatosis susceptibility gene mutations in protecting against iron deficiency in celiac disease. Gastroenterology. 2002;123(2):444-449. No prevalence or incidence reported. [pmid: 12145797].
Buysschaert M. Coeliac disease in patients with type 1 diabetes mellitus and auto-immune thyroid disorders. Acta Gastro-Enterol Belg. 2003;66(3):237-240. Review article.
Cacciari E, Salardi S, Lazzari R, et al. Short stature and celiac disease: a relationship to consider even in patients with no gastrointestinal tract symptoms. Eur J Pediatr. 1983;103(5):708-711. No prevalence or incidence reported.
Cacciari E, Salardi S, Volta U, et al. Antigliadin antibodies in coeliac children with short stature. Lancet. 1985;2(84698470):1434. No prevalence or incidence reported. [pmid: 2867433].
Cacciari E, Salardi S, Volta U, et al. Can antigliadin antibody detect symptomless coeliac disease in children with short stature?. Lancet. 1985;1(8444):1469-1471. No prevalence or incidence reported. [pmid: 2867433].
Cacciari E, Salardi S, Volta U, et al. Prevalence and characteristics of coeliac disease in type 1 diabetes mellitus. Acta Paediatr Scand. 1987;76(4):671-672. Serology screen <1990. [pmid: 3630686].
Caffarelli C, Romanini E, Caruana P, et al. Clinical food hypersensitivity: the relevance of duodenal immunoglobulin E-positive cells. Pediatr Res. 1998;44(4):485-490. No prevalence or incidence reported. [pmid: 9773835].
Caffrey C, Hitman G A, Niven M J, et al. HLA-DP and coeliac disease: family and population studies. Gut. 1990;31(6):663-667. No prevalence or incidence reported. [pmid: 1974234]. [pmcid: 1378492].
Callender J E, Grantham-McGregor S M, Walker S P, et al. Treatment effects in Trichuris dysentery syndrome. Acta Paediatr. 1994;83(11):1182-1187. No prevalence or incidence reported. [pmid: 7531044].
Callender S T, Warner G T. Iron absorption from bread. Am J Clin Nutr. 1968;21(10):1170-1174. No prevalence or incidence reported. [pmid: 5686244].
Calsbeek Hiske, Rijken Mieke, Bekkers Marc J T M, et al. Social position of adolescents with chronic digestive disorders. Eur J Gastroenterol Hepatol. 2002;14(5):543-549. No prevalence or incidence reported. [pmid: 11984153].
Cameron A J, Hoffman H N. Zollinger-Ellison syndrome. Clinical features and long-term follow-up. Mayo Clin Proc. 1974;49(1):44-51. No prevalence or incidence reported. [pmid: 4149030].
Campbell C B, Roberts R K, Cowen A E. The changing clinical presentation of coeliac disease in adults. Med J Aust. 1977;1(4):89-93. No prevalence or incidence reported. [pmid: 557720].
Candy D C, Howard F M, McNeish A S. Familial inherited abnormalities: miscellaneous disorders. Clin Gastroenterol. 1982;11(1):207-229. No prevalence or incidence reported. [pmid: 7037238].
Capristo E, Addolorato G, Mingrone G, et al. Changes in body composition, substrate oxidation, and resting metabolic rate in adult celiac disease patients after a 1-y gluten-free diet treatment. Am J Clin Nutr. 2000;72(1):76-81. No prevalence or incidence reported. [pmid: 10871564].
Carlsson A, Axelsson I, Borulf S, et al. Prevalence of IgA-antigliadin antibodies and IgA-antiendomysium antibodies related to celiac disease in children with Down syndrome. Pediatrics. 1998;101(2):272-275. Not a relevant screening group. [pmid: 9445503].
Carlsson A. Coeliac disease in different child populations. Scand J Nutr Naringsforsk. 2001;45(4):186-187. Review article.
Carlsson Annelie K, Lindberg Bengt A, Bredberg Anders C A, et al. Enterovirus infection during pregnancy is not a risk factor for celiac disease in the offspring. J Pediatr Gastroenterol Nutr. 2002;35(5):649-652. No prevalence or incidence reported. [pmid: 12454580].
Carnicer J, Farre C, Varea V, et al. Prevalence of coeliac disease in Down Syndrome. Eur J Gastroenterol Hepatol. 2001;13(3):263-267. Not a relevant screening group. [pmid: 11293446].
Carpenter C B. Autoimmunity and HLA. J Clin Immunol. 1982;2(3):157-165. No prevalence or incidence reported. [pmid: 6811606].
Carratu R, Secondulfo M, de Magistris L, et al. Altered intestinal permeability to mannitol in diabetes mellitus type I. J Pediatr Gastroenterol Nutr. 1999;28(3):264-269. No prevalence or incidence reported. [pmid: 10067726].
Carrington J M, Hewitt C J, Dowsett L R, et al. The prevalence of coeliac disease in Otago. N Z Med J. 1987;100(828):460-462. Serology screen <1990. [pmid: 3451125].
Carrington J M. Coeliac disease: an analysis of Coeliac Society membership records. N Z Med J. 1986;99(800):279-281. No prevalence or incidence reported. [pmid: 3458081].
Carroccio A, Fontana M, Spagnuolo M I, et al. Pancreatic dysfunction and its association with fat malabsorption in HIV infected children. Gut. 1998;43(4):558-563. No prevalence or incidence reported. [pmid: 9824586]. [pmcid: 1727265].
Carroccio A, Iacono G, Montalto G, et al. Pancreatic enzyme therapy in childhood celiac disease. A double-blind prospective randomized study. Dig Dis Sci. 1995;40(12):2555-2560. No prevalence or incidence reported. [pmid: 8536512].
Carroccio A, Iacono G, Montalto G, et al. Pancreatic insufficiency in celiac disease is not dependent on nutritional status. Dig Dis Sci. 1994;39(10):2235-2242. No prevalence or incidence reported. [pmid: 7924748].
Carroccio A, Iannitto E, Cavataio F, et al. Sideropenic anemia and celiac disease: one study, two points of view. Dig Dis Sci. 1998;43(3):673-678. No prevalence or incidence reported. [pmid: 9539667].
Carroccio A, Pardo F, Montalto G, et al. Use of famotidine in severe exocrine pancreatic insufficiency with persistent maldigestion on enzymatic replacement therapy. A long-term study in cystic fibrosis. Dig Dis Sci. 1992;37(9):1441-1446. No prevalence or incidence reported. [pmid: 1505293].
Carroccio Antonio, Iannitto Emilio, Di Prima, et al. Screening for celiac disease in non-Hodgkin's lymphoma patients: a serum anti-transglutaminase-based approach. Dig Dis Sci. 2003;48(8):1530-1536. No prevalence or incidence reported. [pmid: 12924648].
Carswell F, Gibson A A, McAllister T A. Giardiasis and coeliac disease. Arch Dis Child. 1973;48(6):414-418. No prevalence or incidence reported. [pmid: 4712770].
Carta Mauro, Giovanni Hardoy, Maria Carolina, et al. Association between panic disorder, major depressive disorder and celiac disease: a possible role of thyroid autoimmunity. J Psychosom Res. 2002;53(3):789-793. No prevalence or incidence reported. [pmid: 12217453].
Casellas F, Chicharro L, Malagelada J R. Potential usefulness of hydrogen breath test with D-xylose in clinical management of intestinal malabsorption. Dig Dis Sci. 1993;38(2):321-327. No prevalence or incidence reported. [pmid: 8425444].
Casellas F, Sardi J, De Torres I, et al. Hydrogen breath test with D-xylose for celiac disease screening is as useful in the elderly as in other age groups. Dig Dis Sci. 2001;46(10):2201-2205. No prevalence or incidence reported. [pmid: 11680597].
Caspary W F, Stein J. Diseases of the small intestine. Eur J Gastroenterol Hepatol. 1999;11(1):21-25. No prevalence or incidence reported. [pmid: 10495167].
Castellino F, Scaglione N, Grosso S B, et al. A novel method for detecting IgA endomysial antibodies by using human umbilical vein endothelial cells. Eur J Gastroenterol Hepatol. 2000;12(1):45-49. No prevalence or incidence reported. [pmid: 10656209].
Castro M, Crino A, Papadatou B, et al. Down Syndrome and celiac disease: the prevalence of high IgA-antigliadin antibodies and HLA-DR and DQ antigens in trisomy 21. J Pediatr Gastroenterol Nutr. 1993;16(3):265-268. Not a relevant screening group. [pmid: 8492253].
Cataldo F, Lio D, Marino V, et al. Cytokine genotyping (TNF and IL-10) in patients with celiac disease and selective IgA deficiency. Am J Gastroenterol. 2003;98(4):850-856. No prevalence or incidence reported. [pmid: 12738467].
Cataldo F, Lio D, Marino V, et al. IgG(1) antiendomysium and IgG antitissue transglutaminase (anti-tTG) antibodies in coeliac patients with selective IgA deficiency. Working Groups on Celiac Disease of SIGEP and Club del Tenue. Gut. 2000;47(3):366-369. No prevalence or incidence reported. [pmid: 10940273]. [pmcid: 1728054].
Cataldo F, Marino V, Bottaro G, et al. Celiac disease and selective immunoglobulin A deficiency. Eur J Pediatr. 1997;131(2):306-308. No prevalence or incidence reported.
Cataldo F, Marino V, Di Stefano P. Celiac disease and risk of atopy in childhood. Pediatr Asthma Allergy Immunol. 2001;15(2):77-80. No prevalence or incidence reported.
Cataldo F, Marino V, Ventura A, et al. Prevalence and clinical features of selective immunoglobulin A deficiency in coeliac disease: an Italian multicentre study. Italian Society of Paediatric Gastroenterology and Hepatology (SIGEP) and “Club del Tenue” Working Groups on Coeliac Disease. Gut. 1998;42(3):362-365. No prevalence or incidence reported. [pmid: 9577342]. [pmcid: 1727042].
Cataldo F, Ventura A, Lazzari R, et al. Antiendomysium antibodies and coeliac disease: solved and unsolved questions. An Italian multicentre study. Acta Paediatr. 1995;84(10):1125-1131. No prevalence or incidence reported. [pmid: 8563223].
Cataldo Francesco, Marino Vincenzo. Increased prevalence of autoimmune diseases in first-degree relatives of patients with celiac disease. J Pediatr Gastroenterol Nutr. 2003;36(4):470-473. No prevalence or incidence reported. [pmid: 12658037].
Catassi C, Doloretta Macis M, Ratsch I M, et al. The distribution of DQ genes in the Saharawi population provides only a partial explanation for the high celiac disease prevalence. Tissue Antigens. 2001;58(6):402-406. No prevalence or incidence reported. [pmid: 11929591].
Catassi C, Fabiani E, Ratsch I M, et al. Celiac disease in the general population: should we treat asymptomatic cases?. J Pediatr Gastroenterol Nutr. 1997;24(5):S10-S12. No prevalence or incidence reported. [pmid: 9161968].
Catassi C, Fabiani E. The spectrum of coeliac disease in children. Bailliere's Clinical Gastroenterology. 1997;11(3):485-507. No prevalence or incidence reported. [pmid: 9448912].
Catassi C, Fornaroli F, Fasano A. Celiac disease: From basic immunology to bedside practice. Clin Appl Immunol Rev. 2002;3(12):61-71. No prevalence or incidence reported.
Catassi C, Guerrieri A, Bartolotta E. Antigliadin antibodies at onset of diabetes in children. Lancet. 1987;2(8551):158. No prevalence or incidence reported. [pmid: 2885618].
Catassi C, Ratsch I-M, Gandolfi L, et al. Why is coeliac disease endemic in the people of the Sahara?. Lancet. 1999;354(9179):647-648. No prevalence or incidence reported. [pmid: 10466670].
Catassi Carlo, Fabiani Elisabetta, Corrao Giovanni, et al. Risk of non-Hodgkin lymphoma in celiac disease. Jama - the Journal of the American Medical Association. 2002;287(11):1413-1419. No prevalence or incidence reported. [pmid: 11903028].
Catino M, Tumini S, Mezzetti A, et al. Coeliac disease and diabetes mellitus in children: A non casual association. Diabetes Nutr Metab Clin Exp. 1998;11(5):296-302. No prevalence or incidence reported.
Cavell B, Stenhammar L, Ascher H, et al. Increasing incidence of childhood coeliac disease in Sweden. Results of a national study. Acta Paediatr. 1992;81(8):589-592. Serology screen <1990. [pmid: 1392381].
Ceccarelli M, Caiulo V A, Ughi C. Changing pattern of coeliac disease in western Toscana. Acta Paediatr Scand. 1991;80(5):547-548. No prevalence or incidence reported. [pmid: 1872179].
Cellier C, Cervoni J P, Patey N, et al. Gluten-free diet induces regression of T-cell activation in the rectal mucosa of patients with celiac disease. Am J Gastroenterol. 1998;93(9):1527-1530. No prevalence or incidence reported. [pmid: 9732937].
Cellier C, Cuillerier E, Patey-Mariaud de, et al. Push enteroscopy in celiac sprue and refractory sprue. Gastroenterol Int. 1999;50(5):613-617. No prevalence or incidence reported.
Cellier C, Delabesse E, Helmer C, et al. Refractory sprue, coeliac disease, and enteropathy-associated T-cell lymphoma. French Coeliac Disease Study Group. Lancet. 2000;356(9225):203-208. No prevalence or incidence reported. [pmid: 10963198].
Cervetto J L, Ramonet M, Nahmod L H, et al. Giardiasis. Functional, immunological and histological study of the small bowel. Therapeutic trial with a single dose of tinidazole. Arq Gastroenterol. 1987;24(2):102-112. No prevalence or incidence reported. [pmid: 3333125].
Challacombe D N, Mecrow I K, Elliott K, et al. Changing infant feeding practices and declining incidence of coeliac disease in West Somerset. Arch Dis Child. 1997;77(3):206-209. No prevalence or incidence reported. [pmid: 9370896].
Challacombe D N. The incidence of coeliac disease and early weaning. Arch Dis Child. 1983;58(5):326. No prevalence or incidence reported. [pmid: 6859909].
Chambers T L. Coexistent coeliac disease, diabetes mellitus, and hyperthyroidism. Arch Dis Child. 1975;50(2):162-164. No prevalence or incidence reported. [pmid: 1242879].
Chapman R W, Laidlow J M, Colin-Jones D, et al. Increased prevalence of epilepsy in coeliac disease. Br Med J. 1978;2(6132):250-251. No prevalence or incidence reported. [pmid: 678891]. [pmcid: 1606375].
Chari S T, Mohan V, Jayanthi V, et al. Comparative study of the clinical profiles of alcoholic chronic pancreatitis and tropical chronic pancreatitis in Tamil Nadu, south India. Pancreas. 1992;7(1):52-58. No prevalence or incidence reported. [pmid: 1557346].
Charron D. HLA class II disease associations: Molecular basis. J Autoimmun. 1992;5(Suppl A):45-53. No prevalence or incidence reported. [pmid: 1503635].
Charron D. Molecular basis of human leukocyte antigen class II disease associations. Adv Immunol. 1990;48(-):107-159. No prevalence or incidence reported. [pmid: 2190449].
Chartrand L J, Russo P A, Duhaime A G, et al. Wheat starch intolerance in patients with celiac disease. J Am Diet Assoc. 1997;97(6):612-618. No prevalence or incidence reported. [pmid: 9183321].
Chatzicostas Costantinos, Roussomoustakaki Maria, Drygiannakis Dimitrios, et al. Primary biliary cirrhosis and autoimmune cholangitis are not associated with coeliac disease in Crete. Bmc Gastroenterology Electronic Resource. 2002;2(1):5. No prevalence or incidence reported. [pmid: 11914139]. [pmcid: 102761].
Chernavsky Alejandra C, Rubio Andrea E, Vanzulli Silvia, et al. Evidences of the involvement of Bak, a member of the Bcl-2 family of proteins, in active coeliac disease. Autoimmunity. 2002;35(1):29-37. No prevalence or incidence reported. [pmid: 11908704].
Chiechi L M, Valerio T, Loizzi P. Postmenopausal osteoporosis and celiac disease. Clin Exp Obstet Gynecol. 2002;29(3):187-188. No prevalence or incidence reported. [pmid: 12519039].
Chimenti C, Pieroni M, Frustaci A. Celiac disease in idiopathic dilated cardiomyopathy. Ital Heart J. 2001;2(9):658-659. No prevalence or incidence reported. [pmid: 11666093].
Chin R L, Sander H W, Brannagan T H, et al. Celiac neuropathy. Neurology. 2003;60(10):1581-1585. No prevalence or incidence reported. [pmid: 12771245].
Chinen J, Shearer W T. Basic and clinical immunology. J Allergy Clin Immunol. 2003;111(Suppl 3):S813-S818. No prevalence or incidence reported. [pmid: 12789241].
Chitturi S, Farrell G C. Etiopathogenesis of nonalcoholic steatohepatitis. Semin Liver Dis. 2001;21(1):27-41. No prevalence or incidence reported. [pmid: 11296694].
Chorzelski T P, Olszewska M, Jarzabek-Chorzelska M, et al. Is chronic ulcerative stomatitis an entity? Clinical and immunological findings in 18 cases. Eur J Dermatol. 1998;8(4):261-265. No prevalence or incidence reported. [pmid: 9649663].
Ciacci C, Cavallaro R, Romano R, et al. Increased risk of surgery in undiagnosed celiac disease. Dig Dis Sci. 2001;46(10):2206-2208. No prevalence or incidence reported. [pmid: 11680598].
Ciacci C, Cirillo M, Auriemma G, et al. Celiac disease and pregnancy outcome. Am J Gastroenterol. 1996;91(4):718-722. No prevalence or incidence reported. [pmid: 8677936].
Ciacci C, Cirillo M, Giorgetti G, et al. Low plasma cholesterol: a correlate of nondiagnosed celiac disease in adults with hypochromic anemia. Am J Gastroenterol. 1999;94(7):1888-1891. No prevalence or incidence reported. [pmid: 10406254].
Ciacci C, Cirillo M, Mellone M, et al. Hypocalciuria in overt and subclinical celiac disease. Am J Gastroenterol. 1995;90(9):1480-1484. No prevalence or incidence reported. [pmid: 7661174].
Ciacci C, Cirillo M, Sollazzo R, et al. Gender and clinical presentation in adult celiac disease. Scand J Gastroenterol. 1995;30(11):1077-1081. No prevalence or incidence reported. [pmid: 8578167].
Ciacci C, De Rosa A, de Michele G, et al. Sexual behaviour in untreated and treated coeliac patients. Eur J Gastroenterol Hepatol. 1998;10(8):649-651. No prevalence or incidence reported. [pmid: 9744692].
Ciacci C, Di Vizio D, Seth R, et al. Selective reduction of intestinal trefoil factor in untreated coeliac disease. Clin Exp Immunol. 2002;130(3):526-531. No prevalence or incidence reported. [pmid: 12452845]. [pmcid: 1906543].
Ciacci C, Maurelli L, Klain M, et al. Effects of dietary treatment on bone mineral density in adults with celiac disease: factors predicting response. Am J Gastroenterol. 1997;92(6):992-996. No prevalence or incidence reported. [pmid: 9177517].
Ciacci C, Squillante A, Rendina D, et al. Helicobacter pylori infection and peptic disease in coeliac disease. Eur J Gastroenterol Hepatol. 2000;12(12):1283-1287. No prevalence or incidence reported. [pmid: 11192316].
Ciacci Carolina, Cirillo Massimo, Cavallaro Raimondo, et al. Long-term follow-up of celiac adults on gluten-free diet: prevalence and correlates of intestinal damage. Digestion. 2002;66(3):178-185. No prevalence or incidence reported. [pmid: 12481164].
Ciacci Carolina, Iavarone Alessandro, Siniscalchi Monica, et al. Psychological dimensions of celiac disease: toward an integrated approach. Dig Dis Sci. 2002;47(9):2082-2087. No prevalence or incidence reported. [pmid: 12353859].
Ciampolini M, Bini S. Serum lipids in celiac children. J Pediatr Gastroenterol Nutr. 1991;12(4):459-460. No prevalence or incidence reported. [pmid: 1865279].
Ciclitira P J, Hall M A. Coeliac disease. Bailliere's Clin Gastroenterol. 1990;4(1):43-59. No prevalence or incidence reported. [pmid: 1976395].
Ciclitira P J, Sturgess R. Clinicopathologic mechanisms in celiac disease. Curr Opin Gastroenterol. 1992;8(2):262-267. No prevalence or incidence reported.
Ciclitira P J. Coeliac disease: foreword. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(3):214-215. No prevalence or incidence reported. [pmid: 11990394].
Ciclitira P J. Recent advances in coeliac disease. Clin Med. 2003;3(2):166-169. No prevalence or incidence reported. [pmid: 12737376].
Clemente M G, Musu M P, Frau F, et al. Immune reaction against the cytoskeleton in coeliac disease. Gut. 2000;47(4):520-526. No prevalence or incidence reported. [pmid: 10986212]. [pmcid: 1728086].
Clemente Maria, Grazia Musu, Maria Paola, et al. Antitissue transglutaminase antibodies outside celiac disease. J Pediatr Gastroenterol Nutr. 2002;34(1):31-34. No prevalence or incidence reported. [pmid: 11753161].
Clements M R, Davies M, Hayes M E, et al. The role of 1,25-dihydroxyvitamin D in the mechanism of acquired vitamin D deficiency. Clin Endocrinol (Oxf). 1992;37(1):17-27. No prevalence or incidence reported. [pmid: 1424188].
Clerget-Darpoux F, Bouguerra F, Kastally R, et al. High risk genotypes for celiac disease. Comptes Rendus De L'academie Des Sciences. Serie Iii, Sciences De La Vie. 1994;317(10):931-936. No prevalence or incidence reported.
Clot F, Babron M C, Percopo S, et al. Study of two ectopeptidases in the susceptibility to celiac disease: two newly identified polymorphisms of dipeptidylpeptidase IV. J Pediatr Gastroenterol Nutr. 2000;30(4):464-466. No prevalence or incidence reported. [pmid: 10776965].
Clot F, Fulchignoni-Lataud M C, Renoux C, et al. Linkage and association study of the CTLA-4 region in coeliac disease for Italian and Tunisian populations. Tissue Antigens. 1999;54(5):527-530. No prevalence or incidence reported. [pmid: 10599894].
Clot F, Gianfrani C, Babron M C, et al. HLA-DR53 molecules are associated with susceptibility to celiac disease and selectively bind gliadin-derived peptides. Immunogenetics. 1999;49(9):800-807. No prevalence or incidence reported. [pmid: 10398807].
Cockel R, Anderson C M, Hill E E, et al. Familial steatorrhoea with calcification of the basal ganglia and mental retardation. Gut. 1970;11(12):1064. No prevalence or incidence reported. [pmid: 5511812].
Cockel R, Hill E E, Rushton D I, et al. Familial steatorrhoea with calcification of the basal ganglia and mental retardation. Q J Med. 1973;42(168):771-783. No prevalence or incidence reported. [pmid: 4802475].
Cogulu O, Ozkinay F, Gunduz C, et al. Celiac disease in children with down syndrome: Importance of follow-up and serologic screening. Pediatr Int. 2003;45(4):395-399. No prevalence or incidence reported. [pmid: 12911473].
Colaco J, Egan-Mitchell B, Stevens F M, et al. Compliance with gluten free diet in coeliac disease. Arch Dis Child. 1987;62(7):706-708. No prevalence or incidence reported. [pmid: 3632017].
Cole S G, Kagnoff M F. Celiac disease. Annu Rev Nutr. 1985;5241–266. No prevalence or incidence reported
Coleman M D. Dapsone-mediated agranulocytosis: Risks, possible mechanisms and prevention. Toxicology. 2001;162(1):53-60. No prevalence or incidence reported. [pmid: 11311458].
Colle I, Van Vlierberghe H. Diagnosis and therapeutic problems of primary sclerosing cholangitis. Acta Gastro-Enterol Belg. 2003;66(2):155-159. No prevalence or incidence reported.
Collin P, Hallstrom O, Maki M, et al. Atypical coeliac disease found with serologic screening. Scand J Gastroenterol. 1990;25(3):245-250. No prevalence or incidence reported. [pmid: 2320942].
Collin P, Helin H, Maki M, et al. Follow-up of patients positive in reticulin and gliadin antibody tests with normal small-bowel biopsy findings. Scand J Gastroenterol. 1993;28(7):595-598. No prevalence or incidence reported. [pmid: 8362211].
Collin P, Kaukinen K, Maki M. Clinical features of celiac disease today. Dig Dis. 1999;17(2):100-106. No prevalence or incidence reported. [pmid: 10545715].
Collin P, Korpela M, Hallstrom O, et al. Rheumatic complaints as a presenting symptom in patients with coeliac disease. Scand J Rheumatol. 1992;21(1):20-23. No prevalence or incidence reported. [pmid: 1570482].
Collin P, Pukkala E, Reunala T. Malignancy and survival in dermatitis herpetiformis: a comparison with coeliac disease. Gut. 1996;38(4):528-530. No prevalence or incidence reported. [pmid: 8707082]. [pmcid: 1383109].
Collin P, Reunala T, Pukkala E, et al. Coeliac disease--associated disorders and survival. Gut. 1994;35(9):1215-1218. No prevalence or incidence reported. [pmid: 7959226]. [pmcid: 1375696].
Collin P, Reunala T. Recognition and management of the cutaneous manifestations of celiac disease: A guide for dermatologists. Am J Clin Dermatol. 2003;4(1):13-20. No prevalence or incidence reported. [pmid: 12477369].
Collin P, Salmi J, Hallstrom O, et al. Autoimmune thyroid disorders and coeliac disease. Eur J Endocrinol. 1994;130(2):137-140. No prevalence or incidence reported. [pmid: 8130887].
Collin P, Salmi J, Hallstrom O, et al. High frequency of coeliac disease in adult patients with type-I diabetes. Scand J Gastroenterol. 1989;24(1):81-84. Not a relevant screening geography. [pmid: 2784589].
Collin P, Vilska S, Heinonen P K, et al. Infertility and coeliac disease. Gut. 1996;39(3):382-384. No prevalence or incidence reported. [pmid: 8949641]. [pmcid: 1383343].
Collin Pekka, Kaukinen Katri, Valimaki Matti, et al. Endocrinological disorders and celiac disease. Endocr Rev. 2002;23(4):464-483. No prevalence or incidence reported. [pmid: 12202461].
Collin Pekka, Syrjanen Jaana, Partanen Jukka, et al. Celiac disease and HLA DQ in patients with IgA nephropathy. Am J Gastroenterol. 2002;97(10):2572-2576. Not a relevant screening group. [pmid: 12385441].
Collins B J, Bell P M, Boyd S, et al. Endocrine and exocrine pancreatic function in treated coeliac disease. Pancreas. 1986;1(2):143-147. No prevalence or incidence reported. [pmid: 3554222].
Colomina M J, Puig L, Godet C, et al. Prevalence of asymptomatic cardiac valve anomalies in idiopathic scoliosis. Pediatr Cardiol. 2002;23(4):426-429. No prevalence or incidence reported. [pmid: 12170360].
Colonna M, Bresnahan M, Bahram S, et al. Allelic variants of the human putative peptide transporter involved in antigen processing. Proc Natl Acad Sci U S A. 1992;89(9):3932-3936. No prevalence or incidence reported. [pmid: 1570316]. [pmcid: 525605].
Combarros O, Infante J, Lopez-Hoyos M, et al. Celiac disease and idiopathic cerebellar ataxia. Neurology. 2000;54(12):2346. No prevalence or incidence reported. [pmid: 10881272].
Compston J. Is fracture risk increased in patients with coeliac disease?. Gut. 2003;52(4):459-460. No prevalence or incidence reported. [pmid: 12631649].
Congia M, Cucca F, Frau F, et al. A gene dosage effect of the DQA1*0501/DQB1*0201 allelic combination influences the clinical heterogeneity of celiac disease. Hum Immunol. 1994;40(2):138-142. No prevalence or incidence reported. [pmid: 7928445].
Congia M, Frau F, Lampis R, et al. A high frequency of the A30, B18, DR3, DRw52, DQw2 extended haplotype in Sardinian celiac disease patients: further evidence that disease susceptibility is conferred by DQ A1*0501, B1*0201. Tissue Antigens. 1992;39(2):78-83. No prevalence or incidence reported. [pmid: 1349446].
Cook H B, Burt M J, Collett J A, et al. Adult coeliac disease: prevalence and clinical significance. J Gastroenterol Hepatol. 2000;15(9):1032-1036. Not a relevant screening geography. [pmid: 11059933].
Cooke W T. Symposium. Crohn's disease: medical management. Dis Colon Rectum. 1975;18(3):194-197. No prevalence or incidence reported. [pmid: 1140046].
Cooper A, Brew S, De Lusignan S. The effectiveness of blood tests in detecting secondary osteoporosis or mimicking conditions in postmenopausal women. Br J Gen Pract. 2002;52(477):311-313. No prevalence or incidence reported. [pmid: 11942449]. [pmcid: 1314273].
Cooper B T, Holmes G K, FPERGUSON R, et al. Proceedings: Chronic diarrhoea and gluten sensitivity. Gut. 1976;17(5):398. No prevalence or incidence reported. [pmid: 1278762].
Corazza G R, Biagi F, Volta U, et al. Autoimmune enteropathy and villous atrophy in adults. Lancet. 1997;350(9071):106-109. No prevalence or incidence reported. [pmid: 9228963].
Corazza G R, Caletti G C, Lazzari R, et al. Scalloped duodenal folds in childhood celiac disease. Gastroenterol Int. 1993;39(4):543-545. No prevalence or incidence reported.
Corazza G R, Di Sario A, Cecchetti L, et al. Bone mass and metabolism in patients with celiac disease. Gastroenterology. 1995;109(1):122-128. No prevalence or incidence reported. [pmid: 7797010].
Corazza G R, Di Sario A, Sacco G, et al. Subclinical coeliac disease: an anthropometric assessment. J Intern Med. 1994;236(2):183-187. No prevalence or incidence reported. [pmid: 8046318].
Corazza G R, Di Stefano M, Jorizzo R A, et al. Propeptide of type I procollagen is predictive of posttreatment bone mass gain in adult celiac disease. Gastroenterology. 1997;113(1):67-71. No prevalence or incidence reported. [pmid: 9207263].
Corazza G R, Frisoni M, Filipponi C, et al. Investigation of QT interval in adult coeliac disease. Br Med J. 1992;304(6837):1285. No prevalence or incidence reported. [pmid: 1606432].
Corazza G R, Frisoni M, Treggiari E A, et al. Subclinical celiac sprue. Increasing occurrence and clues to its diagnosis. J Clin Gastroenterol. 1993;16(1):16-21. Not a relevant screening test. [pmid: 8421137].
Corazza G R, Gasbarrini G. Coeliac disease in adults. Bailliere's Clinical Gastroenterology. 1995;9(2):329-350. No prevalence or incidence reported. [pmid: 7549030].
Corazza G R, Zoli G, Di Sabatino A, et al. A reassessment of splenic hypofunction in celiac disease. Am J Gastroenterol. 1999;94(2):391-397. No prevalence or incidence reported. [pmid: 10022635].
Cornes J S. Hodgkin's disease of the gastrointestinal tract. Proc R Soc Med. 1967;60(8):732-733. No prevalence or incidence reported. [pmid: 6035388]. [pmcid: 1901915].
Corrao G, Corazza G R, Andreani M L, et al. Serological screening of coeliac disease: choosing the optimal procedure according to various prevalence values. Gut. 1994;35(6):771-775. No prevalence or incidence reported. [pmid: 8020803]. [pmcid: 1374876].
Corrao G, Corazza G R, Bagnardi V, et al. Mortality in patients with coeliac disease and their relatives: a cohort study. Lancet. 2001;358(9279):356-361. No prevalence or incidence reported. [pmid: 11502314].
Cottone M, Marrone C, Casa A, et al. Familial occurrence of inflammatory bowel disease in celiac disease. Inflamm Bowel Dis. 2003;9(5):321-323. No prevalence or incidence reported. [pmid: 14555916].
Cottone M, Termini A, Oliva L, et al. Mortality and causes of death in celiac disease in a Mediterranean area. Dig Dis Sci. 1999;44(12):2538-2541. No prevalence or incidence reported. [pmid: 10630509].
Cottrill C, Glueck C J, Leuba V, et al. Familial homozygous hypobetalipoproteinemia. Metabolism-Clinical and Experimental. 1974;23(8):779-791. No prevalence or incidence reported. [pmid: 4368720].
Cowan B, Satija V K, Malvea B P. Steatorrhoea in the Punjab: the results of a village survey. Am J Trop Med Hyg. 1971;74(6):137-140. No prevalence or incidence reported.
Cowan B. Malnutrition and malabsorption: studies in the Punjab. Am J Clin Nutr. 1972;25(11):1234-1235. No prevalence or incidence reported. [pmid: 5086045].
Cox M A, Iqbal T H, Cooper B T, et al. An analytical method for the quantitation of mannitol and disaccharides in serum: a potentially useful technique in measuring small intestinal permeability in vivo. Clin Chim Acta. 1997;263(2):197-205. No prevalence or incidence reported. [pmid: 9246424].
Crandall C. Laboratory workup for osteoporosis: Which tests are most cost-effective?. Postgrad Med. 2003;114(3):35-44. No prevalence or incidence reported. [pmid: 14503399].
Cremata J A, Sorell L, Montesino R, et al. Hypogalactosylation of serum IgG in patients with coeliac disease. Clin Exp Immunol. 2003;133(3):422-429. No prevalence or incidence reported. [pmid: 12930370]. [pmcid: 1808795].
Crenn Pascal, Vahedi Kouroche, Lavergne-Slove Anne, et al. Plasma citrulline: A marker of enterocyte mass in villous atrophy-associated small bowel disease. Gastroenterology. 2003;124(5):1210-1219. No prevalence or incidence reported. [pmid: 12730862].
Croft D N. Body iron loss and cell loss from epithelia. Proc R Soc Med. 1970;63(12):1221-1224. No prevalence or incidence reported. [pmid: 5490767]. [pmcid: 1812398].
Cronin C C, Jackson L M, Feighery C, et al. Coeliac disease and epilepsy. Qjm - Monthly Journal of the Association of Physicians. 1998;91(4):303-308. No prevalence or incidence reported. [pmid: 9666954].
Cronin C C, Shanahan F. Exploring the iceberg - The spectrum of celiac disease. Am J Gastroenterol. 2003;98(3):518-520. No prevalence or incidence reported. [pmid: 12650779].
Cronin C C, Shanahan F. Insulin-dependent diabetes mellitus and coeliac disease. Lancet. 1997;349(9058):1096-1097. No prevalence or incidence reported. [pmid: 9107261].
Cronin C C, Shanahan F. Why is celiac disease so common in Ireland?. Perspect Biol Med. 2001;44(3):342-352. No prevalence or incidence reported. [pmid: 11482004].
Crowe J P, Falini N P. Gluten in pharmaceutical products. Am J Health-Syst Pharm. 2001;58(5):396-401. No prevalence or incidence reported. [pmid: 11258175].
Csizmadia C G, Mearin M L, Oren A, et al. Accuracy and cost-effectiveness of a new strategy to screen for celiac disease in children with Down syndrome. Eur J Pediatr. 2000;137(6):756-761. Not a relevant screening group.
Cudworth A G, Woodrow J C. HL-A system and diabetes mellitus. Diabetes. 1975;24(4):345-349. No prevalence or incidence reported. [pmid: 48487].
Cummins A G, Thompson F M, Butler R N, et al. Improvement in intestinal permeability precedes morphometric recovery of the small intestine in coeliac disease. Clinical Science (London, England - 1979). 2001;100(4):379-386. No prevalence or incidence reported. [pmid: 11256975].
Cunningham A S, Jelliffe D B, Jelliffe E F. Breast-feeding and health in the 1980s: a global epidemiologic review. Eur J Pediatr. 1991;118(5):659-666. No prevalence or incidence reported.
Cuoco L, Cammarota G, Jorizzo R A, et al. Link between Helicobacter pylori infection and iron-deficiency anaemia in patients with coeliac disease. Scand J Gastroenterol. 2001;36(12):1284-1288. No prevalence or incidence reported. [pmid: 11761018].
Cuoco L, Cammarota G, Tursi A, et al. Disappearance of gastric mucosa-associated lymphoid tissue in coeliac patients after gluten withdrawal. Scand J Gastroenterol. 1998;33(4):401-405. No prevalence or incidence reported. [pmid: 9605262].
Cuoco L, Certo M, Jorizzo R A, et al. Prevalence and early diagnosis of coeliac disease in autoimmune thyroid disorders. Ital J Gastroenterol Hepatol. 1999;31(4):283-287. No prevalence or incidence reported. [pmid: 10425571].
Cuomo A, Romano M, Rocco A, et al. Reflux oesophagitis in adult coeliac disease: beneficial effect of a gluten free diet. Gut. 2003;52(4):514-517. No prevalence or incidence reported. [pmid: 12631661]. [pmcid: 1773586].
Curione M, Barbato M, De Biase L, et al. Prevalence of coeliac disease in idiopathic dilated cardiomyopathy. Lancet. 1999;354(9174):222-223. No prevalence or incidence reported. [pmid: 10421311].
Czaja A J. Autoimmune liver disease. Curr Opin Gastroenterol. 1999;15(3):240-248. No prevalence or incidence reported. [pmid: 17023951].
Czaja A J. Autoimmune liver disease. Curr Opin Gastroenterol. 2003;19(3):232-242. No prevalence or incidence reported. [pmid: 15703563].
Dahan S, Slater P E, Cooper M, et al. Coeliac disease in the Rehovot-Ashdod region of Israel: incidence and ethnic distribution. J Epidemiol Community Health. 1984;38(1):58-60. Not a relevant screening geography. [pmid: 6608573].
Dahele A V, Aldhous M C, Humphreys K, et al. Serum IgA tissue transglutaminase antibodies in coeliac disease and other gastrointestinal diseases. Qjm - Monthly Journal of the Association of Physicians. 2001;94(4):195-205. No prevalence or incidence reported. [pmid: 11294962].
Dahele A, Ghosh S. Vitamin B12 deficiency in untreated celiac disease. Am J Gastroenterol. 2001;96(3):745-750. No prevalence or incidence reported. [pmid: 11280545].
Dahele A, Kingstone K, Bode J, et al. Anti-endomysial antibody negative celiac disease: does additional serological testing help?. Dig Dis Sci. 2001;46(1):214-221. No prevalence or incidence reported. [pmid: 11270789].
Dahlqvist G. Celiac disease and insulin-dependent diabetes mellitus--no proof for a causal association. Acta Paediatr. 1995;84(12):1337-1338. No prevalence or incidence reported. [pmid: 8645946].
Damen G M, Boersma B, Wit J M, et al. Catch-up growth in 60 children with celiac disease. J Pediatr Gastroenterol Nutr. 1994;19(4):394-400. No prevalence or incidence reported. [pmid: 7876992].
Damoiseaux Jan G M C, Bouten Bas, Linders Annick M L W, et al. Diagnostic value of anti-Saccharomyces cerevisiae and antineutrophil cytoplasmic antibodies for inflammatory bowel disease: high prevalence in patients with celiac disease. J Clin Immunol. 2002;22(5):281-288. No prevalence or incidence reported. [pmid: 12405161].
Danne T. Current issues in paediatric diabetology: Introduction to meet-the-expert sessions. Horm Res. 2002;57(Suppl 1):91-92. No prevalence or incidence reported. [pmid: 11979033].
Dausset J. Biologic role of the HLA system. HLA complex in human biology in the light of associations with disease. Transplant Proc. 1977;9(1):523-529. No prevalence or incidence reported. [pmid: 867501].
David T J, Ajdukiewicz A B. A family study of coeliac disease. J Med Genet. 1975;12(1):79-82. Serology screen <1990. [pmid: 1121023].
Davis M K. Breastfeeding and chronic disease in childhood and adolescence. Pediatr Clin North Am 2001;48(1):125–41, Ix. No prevalence or incidence reported
Davison S. Coeliac disease and liver dysfunction. Arch Dis Child. 2002;87(4):293-296. No prevalence or incidence reported. [pmid: 12243999].
Dawood F H, Jabbar A A, Al Mudaris A F, et al. Association of HLA antigens with coeliac disease among Iraqi children. Tissue Antigens. 1981;18(1):35-39. No prevalence or incidence reported. [pmid: 6949339].
Dawson A M. Nutritional disturbances in Crohn's disease. Br J Surg. 1972;59(10):817-819. No prevalence or incidence reported. [pmid: 5077895].
Dawson A M. Nutritional disturbances in Crohn's disease. Proc R Soc Med. 1971;64(2):166-170. No prevalence or incidence reported. [pmid: 5548941]. [pmcid: 1812419].
de Francischi M L, Salgado J M, da Costa C P. Immunological analysis of serum for buckwheat fed celiac patients. Plant Foods Hum Nutr. 1994;46(3):207-211. No prevalence or incidence reported. [pmid: 7855091].
de Freitas I, Sipahi Aytan, Miranda Damiao, et al. Celiac disease in Brazilian adults. J Clin Gastroenterol. 2002;34(4):430-434. No prevalence or incidence reported. [pmid: 11907355].
De Giacomo C, Gianatti A, Negrini R, et al. Lymphocytic gastritis: a positive relationship with celiac disease. Eur J Pediatr. 1994;124(1):57-62. No prevalence or incidence reported.
de la, Concha E G, Fernandez-Arquero M, et al. Celiac disease and TNF promoter polymorphisms. Hum Immunol. 2000;61(5):513-517. No prevalence or incidence reported. [pmid: 10773355].
de la, Paz Bettinotti M, Kolek A, et al. Polymorphism of the 5′ flanking region of the HLA-DQA1 gene in coeliac disease. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1993;20(5):399-407. No prevalence or incidence reported. [pmid: 9098408].
de Lecea A, Ribes-Koninckx C, Polanco I, et al. Serological screening (antigliadin and antiendomysium antibodies) for non-overt coeliac disease in children of short stature. Acta Paediatr. 1996;412(Suppl):54-55. No prevalence or incidence reported.
de Vizia B, Poggi V, Conenna R, et al. Iron absorption and iron deficiency in infants and children with gastrointestinal diseases. J Pediatr Gastroenterol Nutr. 1992;14(1):21-26. No prevalence or incidence reported. [pmid: 1573507].
Dean G, Hanniffy L, Stevens F, et al. Schizophrenia and coeliac disease. Ir Med J. 1975;68(21):545-546. No prevalence or incidence reported. [pmid: 1052488].
Del Rosario M A, Fitzgerald J F, Chong S K, et al. Further studies of anti-endomysium and anti-gliadin antibodies in patients with suspected celiac disease. J Pediatr Gastroenterol Nutr. 1998;27(2):191-195. No prevalence or incidence reported. [pmid: 9702652].
Delco F, El Serag H B, Sonnenberg A. Celiac sprue among US military veterans: associated disorders and clinical manifestations. Dig Dis Sci. 1999;44(5):966-972. No prevalence or incidence reported. [pmid: 10235605].
DeMarchi M, Borelli I, Olivetti E, et al. Two HLA-D and DR alleles are associated with coeliac disease. Tissue Antigens. 1979;14(4):309-316. No prevalence or incidence reported. [pmid: 94703].
DeMarchi M, Carbonara A, Ansaldi N, et al. HLA-DR3 and DR7 in coeliac disease: immunogenetic and clinical aspects. Gut. 1983;24(8):706-712. No prevalence or incidence reported. [pmid: 6603391]. [pmcid: 1420226].
Demir H, Yuce A, Kocak N, et al. Celiac disease in Turkish children: presentation of 104 cases. Pediatrics International - Official Journal of the Japan Pediatric Society. 2000;42(5):483-487. No prevalence or incidence reported. [pmid: 11059535].
Dennis N R, Stokes C R. Risk of coeliac disease in children of patients and effect of HLA genotype. J Med Genet. 1978;15(1):20-22. No prevalence or incidence reported. [pmid: 633317].
Deprez Pierre H, Sempoux Christine, De Saeger, et al. Expression of cholecystokinin in the duodenum of patients with coeliac disease: respective role of atrophy and lymphocytic infiltration. Clinical Science (London, England - 1979). 2002;103(2):171-177. No prevalence or incidence reported. [pmid: 12149109].
der Ohe M R. Diarrhoea in patients with diabetes mellitus. Eur J Gastroenterol Hepatol. 1995;7(8):730-736. No prevalence or incidence reported. [pmid: 7496860].
Desjeux Ariadne, Barthet Marc, Barthellemy Sandrine, et al. Serum measurements of pancreatitis associated protein in active Crohn's disease with ileal location. Gastroenterol Clin Biol. 2002;26(1):23-28. No prevalence or incidence reported. [pmid: 11938036].
Devi Rampertab S, Fleischauer A, Neugut A I, et al. Risk of duodenal adenoma in celiac disease. Scand J Gastroenterol. 2003;38(8):831-833. No prevalence or incidence reported. [pmid: 12940435].
Dewar D, Pereira S P, Ciclitira P J. The pathogenesis of coeliac disease. Int J Biochem Cell Biol. 2004;36(1):17-24. No prevalence or incidence reported. [pmid: 14592529].
Dezi R, Niveloni S, Sugai E, et al. Gluten sensitivity in the rectal mucosa of first-degree relatives of celiac disease patients. Am J Gastroenterol. 1997;92(8):1326-1330. No prevalence or incidence reported. [pmid: 9260799].
Dhesi I, Marsh M N, Kelly C, et al. Morphometric analysis of small intestinal mucosa. II. Determination of lamina propria volumes; plasma cell and neutrophil populations within control and coeliac disease mucosae. Virchows Archiv. A, Pathological Anatomy and Histopathology. 1984;403(2):173-180. No prevalence or incidence reported.
Di Mario U, Anastasi E, Mariani P, et al. Diabetes-related autoantibodies do appear in children with coeliac disease. Acta Paediatr. 1992;81(8):593-597. No prevalence or incidence reported. [pmid: 1392382].
Di Sabatino A, Bertrandi E, Casadei Maldini M, et al. Phenotyping of peripheral blood lymphocytes in adult coeliac disease. Immunology. 1998;95(4):572-576. No prevalence or incidence reported. [pmid: 9893047]. [pmcid: 1364354].
Di Sabatino A, Ciccocioppo R, D'Alo S, et al. Intraepithelial and lamina propria lymphocytes show distinct patterns of apoptosis whereas both populations are active in Fas based cytotoxicity in coeliac disease. Gut. 2001;49(3):380-386. No prevalence or incidence reported. [pmid: 11511560]. [pmcid: 1728419].
Di Stefano M, Jorizzo R A, Veneto G, et al. Bone mass and metabolism in dermatitis herpetiformis. Dig Dis Sci. 1999;44(10):2139-2143. No prevalence or incidence reported. [pmid: 10548369].
Di Stefano M, Veneto G, Corrao G, et al. Role of lifestyle factors in the pathogenesis of osteopenia in adult coeliac disease: a multivariate analysis. Eur J Gastroenterol Hepatol. 2000;12(11):1195-1199. No prevalence or incidence reported. [pmid: 11111775].
Di Stefano, Michele Miceli, Emanuela Malservisi, et al. Mixing of the intestinal content and variations of fermentation capacity do not affect the results of hydrogen breath test. Am J Gastroenterol. 2003;98(7):1584-1587. No prevalence or incidence reported. [pmid: 12873582].
Diamanti A, Maino C, Niveloni S, et al. Characterization of gastric mucosal lesions in patients with celiac disease: a prospective controlled study. Am J Gastroenterol. 1999;94(5):1313-1319. No prevalence or incidence reported. [pmid: 10235212].
Dickey W, Bodkin S. Prospective study of body mass index in patients with coeliac disease. BMJ. 1998;317(7168):2190. No prevalence or incidence reported. [pmid: 9804717].
Dickey W, Hughes D F, McMillan S A. Disappearance of endomysial antibodies in treated celiac disease does not indicate histological recovery. Am J Gastroenterol. 2000;95(3):712-714. No prevalence or incidence reported. [pmid: 10710062].
Dickey W, Hughes D F, McMillan S A. Reliance on serum endomysial antibody testing underestimates the true prevalence of coeliac disease by one fifth. Scand J Gastroenterol. 2000;35(2):181-183. No prevalence or incidence reported. [pmid: 10720117].
Dickey W, Hughes D. Disappointing sensitivity of endoscopic markers for villous atrophy in a high-risk population: implications for celiac disease diagnosis during routine endoscopy. Am J Gastroenterol. 2001;96(7):2126-2128. No prevalence or incidence reported. [pmid: 11467643].
Dickey W, Hughes D. Prevalence of celiac disease and its endoscopic markers among patients having routine upper gastrointestinal endoscopy. Am J Gastroenterol. 1999;94(8):2182-2186. No prevalence or incidence reported. [pmid: 10445547].
Dickey W, McConnell J B. How many hospital visits does it take before celiac sprue is diagnosed?. J Clin Gastroenterol. 1996;23(1):21-23. No prevalence or incidence reported. [pmid: 8835909].
Dickey W, McMillan S A, Callender M E. High prevalence of celiac sprue among patients with primary biliary cirrhosis. J Clin Gastroenterol. 1997;25(1):328-329. No prevalence or incidence reported. [pmid: 9412913].
Dickey W, McMillan S A, Collins J S, et al. Liver abnormalities associated with celiac sprue. How common are they, what is their significance, and what do we do about them?. J Clin Gastroenterol. 1995;20(4):290-292. No prevalence or incidence reported. [pmid: 7665816].
Dickey W, McMillan S A, Hughes D F. Identification of coeliac disease in primary care. Scand J Gastroenterol. 1998;33(5):491-493. No prevalence or incidence reported. [pmid: 9648987].
Dickey W, McMillan S A, Hughes D F. Sensitivity of serum tissue transglutaminase antibodies for endomysial antibody positive and negative coeliac disease. Scand J Gastroenterol. 2001;36(5):511-514. No prevalence or incidence reported. [pmid: 11346205].
Dickey W, McMillan S A, McCrum E E, et al. Association between serum levels of total IgA and IgA class endomysial and antigliadin antibodies: implications for coeliac disease screening. Eur J Gastroenterol Hepatol. 1997;9(6):559-562. No prevalence or incidence reported. [pmid: 9222726].
Dickey W. Colon neoplasia co-existing with coeliac disease in older patients: coincidental, probably; important, certainly. Scand J Gastroenterol. 2002;37(9):1054-1056. No prevalence or incidence reported. [pmid: 12374231].
Dickey W. Diagnosis of coeliac disease at open-access endoscopy. Scand J Gastroenterol. 1998;33(6):612-615. No prevalence or incidence reported. [pmid: 9669633].
Dickey W. Low serum vitamin B12 is common in coeliac disease and is not due to autoimmune gastritis. Eur J Gastroenterol Hepatol. 2002;14(4):425-427. No prevalence or incidence reported. [pmid: 11943958].
Dieterich W, Ehnis T, Bauer M, et al. Identification of tissue transglutaminase as the autoantigen of celiac disease. Nat Med. 1997;3(7):797-801. No prevalence or incidence reported. [pmid: 9212111].
Dissanayake A S, Truelove S C, Whitehead R. Jejunal mucosal recovery in coeliac disease in relation to the degree of adherence to a gluten-free diet. Q J Med. 1974;43(170):161-185. No prevalence or incidence reported. [pmid: 4604652].
Djilali-Saiah I, Benini V, Schmitz J, et al. Absence of primary association between DM gene polymorphism and insulin-dependent diabetes mellitus or celiac disease. Hum Immunol. 1996;49(1):22-27. No prevalence or incidence reported. [pmid: 8839772].
Djilali-Saiah I, Caillat-Zucman S, Schmitz J, et al. Polymorphism of antigen processing (TAP, LMP) and HLA class II genes in celiac disease. Hum Immunol. 1994;40(1):8-16. No prevalence or incidence reported. [pmid: 8045794].
Djilali-Saiah I, Schmitz J, Harfouch-Hammoud E, et al. CTLA-4 gene polymorphism is associated with predisposition to coeliac disease. Gut. 1998;43(2):187-189. No prevalence or incidence reported. [pmid: 10189842]. [pmcid: 1727221].
Dobru D, Pascu O, Tant cedil, et al. The prevalence of coeliac disease at endoscopy units in Romania: Routine biopsies during gastroscopy are mandatory (A multicentre study). Rom J Gastroenterol. 2003;12(2):97-100. Not a relevant screening geography. [pmid: 12853994].
Dohan F C, Harper E H, Clark M H, et al. Is schizophrenia rare if grain is rare?. Biol Psychiatry. 1984;19(3):385-399. No prevalence or incidence reported. [pmid: 6609726].
Dohan F C. Cereals and schizophrenia data and hypothesis. Acta Psychiatr Scand. 1966;42(2):125-152. No prevalence or incidence reported. [pmid: 5959639].
Dohan F C. The possible pathogenic effect of cereal grains in schizophrenia. Celiac disease as a model. Acta Neurol (Napoli). 1976;31(2):195-205. No prevalence or incidence reported. [pmid: 1007983].
Driessen A, Ectors N. Lymphomas of the gastro-intestinal tract: Uncommon types: LYMPHOMES DU TRACTUS GASTRO-INTESTINAL: TYPES RARES. Acta Endoscopica. 2003;33(3):327-345. No prevalence or incidence reported.
Drury M I, Keelan D M, Timoney F J, et al. Juvenile familial endocrinopathy. Clin Exp Immunol. 1970;7(1):125-132. No prevalence or incidence reported. [pmid: 5202743]. [pmcid: 1712715].
Dugoujon J M, Cambon-Thomsen A. Immunoglobulin allotypes (GM and KM) and their interactions with HLA antigens in autoimmune diseases: A review. Autoimmunity. 1995;22(4):245-260. No prevalence or incidence reported. [pmid: 8781716].
Dugoujon J M, Guitard E, Senegas M T. Gm and Km allotypes in autoimmune diseases. G Ital Cardiol. 1992;22(1):85-95. No prevalence or incidence reported. [pmid: 1624073].
Duncan A, Park R P, Lee F D, et al. A retrospective assessment of the clinical value of jejunal disaccharidase analysis. Scand J Gastroenterol. 1994;29(12):1111-1116. No prevalence or incidence reported. [pmid: 7886399].
Dunger David, Ahmed Lynn, Ong Ken. Growth and body composition in type 1 diabetes mellitus. Horm Res. 2002;58(Suppl 1):66-71. No prevalence or incidence reported. [pmid: 12373017].
Dyer N H, Rutherford C, Visick J H, et al. The incidence and reliability of individual radiographic signs in the small intestine in Crohn's disease. Br J Radiol. 1970;43(510):401-408. No prevalence or incidence reported. [pmid: 5427467].
Eastell Richard. Management of osteoporosis due to ovarian failure. Med Pediatr Oncol. 2003;41(3):222-227. No prevalence or incidence reported. [pmid: 12868123].
Ebisawa M, Ikematsu K, Imai T, et al. Food Allergy in Japan. Allergy Clin Immunol Int. 2003;15(5):214-217. No prevalence or incidence reported.
Ebo D G, Stevens W J. IgE-mediated food allergy - Extensive review of the literature. Acta Clin Belg. 2001;56(4):234-247. No prevalence or incidence reported. [pmid: 11603253].
Ectors N. Infectious disorders of the duodenum: MALADIES INFECTIEUSES DU DUODENUM. Acta Endoscopica. 2002;32(2):133-156. No prevalence or incidence reported.
Egan C A, O'Loughlin S, Gormally S, et al. Dermatitis Herpetiformis: a review of fifty-four patients. Ir J Med Sci. 1997;166(4):241-244. No prevalence or incidence reported. [pmid: 9394075].
Egan L J, Walsh S V, Stevens F M, et al. Celiac-associated lymphoma. A single institution experience of 30 cases in the combination chemotherapy era. J Clin Gastroenterol. 1995;21(2):123-129. No prevalence or incidence reported. [pmid: 8583077].
Ehrlich R M. Diabetes mellitus in childhood. Pediatr Clin North Am. 1974;21(4):871-884. No prevalence or incidence reported. [pmid: 4215063].
Eichler I, Frisch H, Granditsch G. Growth failure and insulin-like growth factor (IGF-I) in childhood celiac disease. Klin Wochenschr. 1991;69(18):825-829. No prevalence or incidence reported. [pmid: 1770750].
Eiermann T H, Vejbaesya S, Prestel H, et al. Association and linkage of human leukocyte antigens with psoriasis - Revisited. Infusther Transfusionsmed. 2002;29(6):326-330. No prevalence or incidence reported.
Eigenmann P A, Calza A-M. Diagnosis of IgE-mediated food allergy among Swiss children with atopic dermatitis. Pediatr Allergy Immunol. 2000;11(2):95-100. No prevalence or incidence reported. [pmid: 10893011].
Eigenmann P A, Sampson H A. Interpreting skin prick tests in the evaluation of food allergy in children. Pediatric Allergy and Immunology - Official Publication of the European Society of Pediatric Allergy and Immunology. 1998;9(4):186-191. No prevalence or incidence reported. [pmid: 9920216].
Eigenmann P A, Sicherer S H, Borkowski T A, et al. Prevalence of IgE-mediated food allergy among children with atopic dermatitis. Pediatric. 1998;101(4):E8. No prevalence or incidence reported.
Ek B. On the familiar incidence of idiopathic sprue and the significance of pregnancy and partial gastrectomy for the manifestation of the symptoms. Preliminary report. Acta Med Scand. 1967;181(1):125-126. No prevalence or incidence reported. [pmid: 6016990].
Ek B. Studies on idiopathic non-tropical sprue. The familial occurrence of sprue. Relationship between sprue and megaloblastic anaemia of pregnancy and puerperium. The significance of partial gastrectomy for manifestation of symptoms. Acta Med Scand. 1970;508(Suppl):1-72. No prevalence or incidence reported.
Ekbom A, Adami H-O. The epidemiology of inflammatory bowel disease. Curr Opin Gastroenterol. 1991;7(4):649-653. No prevalence or incidence reported.
El Salhy M, Suhr O, Danielsson A. Peptide YY in gastrointestinal disorders. Peptides. 2002;23(2):397-402. No prevalence or incidence reported. [pmid: 11825655].
Eliakim R, Sherer D M. Celiac disease: fertility and pregnancy. Gynecol Obstet Invest. 2001;51(1):3-7. No prevalence or incidence reported. [pmid: 11223697].
Ellis A, Taylor C J, Dillon-Remmy M, et al. HLA-DR typing in coeliac disease: evidence for genetic heterogeneity. Br Med J (Clin Res Ed). 1984;289(6458):1571-1573. No prevalence or incidence reported. [pmid: 6439322].
Ellis A. The genetic epidemiology of coeliac disease. Genet Epidemiol. 1986;1(Suppl):267-269. No prevalence or incidence reported.
Ellman L K, Chatchatee P, Sicherer S H, et al. Food hypersensitivity in two groups of children and young adults with atopic dermatitis evaluated a decade apart. Pediatr Allergy Immunol. 2002;13(4):295-298. No prevalence or incidence reported. [pmid: 12390446].
Elmes M E, Jones J G, Stanton M R. Changes in the Paneth cell population of human small intestine assessed by image analysis of the secretory granule area. J Clin Pathol. 1983;36(8):867-872. No prevalence or incidence reported. [pmid: 6875016]. [pmcid: 498414].
Elsborg L, Mosbech J. Sprue: a follow-up study of an old series. Dan Med Bull. 1978;25(5):205-206. No prevalence or incidence reported. [pmid: 699635].
Endres W, Wuttge B. Occurrence of secondary cystathioninuria in children with inherited metabolic disorders, liver diseases, neoplasms, cystic fibrosis and celiac disease. Eur J Pediatr. 1978;129(1):29-35. No prevalence or incidence reported. [pmid: 210019].
Engstrom J, Hellstrom K, Lundh G, et al. Microflora of small intestine, incidence of steatorrhoea and indicanuria before and after conversion of billroth II to billroth I type of gastric resection. Acta Chir Scand. 1973;139(6):546-550. No prevalence or incidence reported. [pmid: 4753104].
Engstrom J, Hellstrom K. Microflora of the small intestine and the incidence of liver disease, steatorrhoea, and indicanuria in patients subjected to partial gastrectomy. Acta Chir Scand. 1973;139(6):539-545. No prevalence or incidence reported. [pmid: 4753104].
Ensari A, Marsh M N, Loft D E, et al. Morphometric analysis of intestinal mucosa. V. Quantitative histological and immunocytochemical studies of rectal mucosae in gluten sensitivity. Gut. 1993;34(9):1225-1229. No prevalence or incidence reported. [pmid: 8406159]. [pmcid: 1375459].
Ensari A, Marsh M N, Morgan S, et al. Diagnosing coeliac disease by rectal gluten challenge: a prospective study based on immunopathology, computerized image analysis and logistic regression analysis. Clinical Science (London, England - 1979). 2001;101(2):199-207. No prevalence or incidence reported. [pmid: 11473497].
Erkan T, Kutlu T, Yilmaz E, et al. Human leukocyte antigens in Turkish pediatric celiac patients. Turk J Pediatr. 1999;41(2):181-188. No prevalence or incidence reported. [pmid: 10770656].
Evans W B, Wollaeger E E. Incidence and severity of nutritional deficiency states in chronic exocrine pancreatic insufficency: comparison with nontropical sprue. Am J Dig Dis. 1966;11(8):594-606. No prevalence or incidence reported. [pmid: 5943765].
Everts B, Stotzer P, Olsson M, et al. Increased luminal nitric oxide concentrations in the small intestine of patients with coeliac disease. Eur J Clin Invest. 1999;29(8):692-696. No prevalence or incidence reported. [pmid: 10457153].
Exner G U, Sacher M, Shmerling D H, et al. Growth retardation and bone mineral status in children with coeliac disease recognized after the age of 3 years. Helv Paediatr Acta. 1978;33(6):497-507. No prevalence or incidence reported. [pmid: 216653].
Eysink P E D, Bindels P J E, Stapel S O, et al. Do levels of immunoglobulin G antibodies to foods predict the development of immunoglobulin E antibodies to cat, dog and/or mite?. Clin Exp Allergy. 2002;32(4):556-562. No prevalence or incidence reported. [pmid: 11972602].
Eysink P E, De Jong M H, Bindels P J, et al. Relation between IgG antibodies to foods and IgE antibodies to milk, egg, cat, dog and/or mite in a cross-sectional study. Clinical and Experimental Allergy - Journal of the British Society for Allergy and Clinical Immunology. 1999;29(5):604-610. No prevalence or incidence reported. [pmid: 10231319].
Fabiani E, Catassi C, Villari A, et al. Dietary compliance in screening-detected coeliac disease adolescents. Acta Paediatr. 1996;412(Suppl):65-67. No prevalence or incidence reported.
Fabiani E, Taccari L M, Ratsch I M, et al. Compliance with gluten-free diet in adolescents with screening-detected celiac disease: a 5-year follow-up study. Eur J Pediatr. 2000;136(6):841-843. No prevalence or incidence reported.
Failla P, Ruberto C, Pagano M C, et al. Celiac disease in Down Syndrome with HLA serological and molecular studies. J Pediatr Gastroenterol Nutr. 1996;23(3):303-306. No prevalence or incidence reported. [pmid: 8890082].
Fakhri Z I. Causes of hypersensitivity reactions in flour mill workers in Sudan. Occup Med. 1992;42(3):149-154. No prevalence or incidence reported.
Falchuk Z M, Katz A J, Shwachman H, et al. Gluten-sensitive enteropathy: genetic analysis and organ culture study in 35 families. Scand J Gastroenterol. 1978;13(7):839-843. No prevalence or incidence reported. [pmid: 82994].
Falk M C, NG G, Zhang G Y, et al. Predominance of T cell receptor V delta 3 in small bowel biopsies from coeliac disease patients. Clin Exp Immunol. 1994;98(1):78-82. No prevalence or incidence reported. [pmid: 7923889]. [pmcid: 1534169].
Faloon W W, Flood M S, Aroesty S, et al. Assessment of jejunoileostomy for obesity--some observations since 1976. Am J Clin Nutr. 1980;33(2 Suppl):431-439. No prevalence or incidence reported. [pmid: 7355816].
Falth-Magnusson K, Franzen L, Jansson G, et al. Infant feeding history shows distinct differences between Swedish celiac and reference children. Pediatric Allergy and Immunology - Official Publication of the European Society of Pediatric Allergy and Immunology. 1996;7(1):1-5. No prevalence or incidence reported. [pmid: 8792377].
Falzon L. Topic: Gluten-free diet of coeliac disease. J Clin Excellence. 2001;3(4):209-211. No prevalence or incidence reported.
Farre C, Esteve M, Curcoy A, et al. Hypertransaminasemia in pediatric celiac disease patients and its prevalence as a diagnostic clue. Am J Gastroenterol. 2002;97(12):3176-3181. No prevalence or incidence reported. [pmid: 12492207].
Farrell R J, Kelly C P. Diagnosis of celiac sprue. Am J Gastroenterol. 2001;96(12):3237-3246. Review article. [pmid: 11774931].
Farrell Richard J, Kelly Ciaran P. Celiac sprue. N Engl J Med. 2002;346(3):180-188. No prevalence or incidence reported. [pmid: 12168643].
Fasano A, Catassi C. Current approaches to diagnosis and treatment of celiac disease: an evolving spectrum. Gastroenterology. 2001;120(3):636-651. No prevalence or incidence reported. [pmid: 11179241].
Fasano A. European and North American populations should be screened for coeliac disease. Gut. 2003;52(2):168-169. No prevalence or incidence reported. [pmid: 12524403]. [pmcid: 1774954].
Fasano A. Where have all the American celiacs gone?. Acta Paediatr. 1996;412(Suppl):20-24. No prevalence or incidence reported.
Fasano Alessio. Celiac disease--how to handle a clinical chameleon. N Engl J Med. 2003;348(25):2568-2570. No prevalence or incidence reported. [pmid: 12815143].
Fdez-Morera J L, Rodrigo L, Lopez-Vazquez A, et al. MHC class I chain-related gene a transmembrane polymorphism modulates the extension of ulcerative colitis. Hum Immunol. 2003;64(8):816-822. No prevalence or incidence reported. [pmid: 12878361].
Fedrick J A, Pandey J P, Verkasalo M, et al. Immunoglobulin allotypes and the immune response to wheat gliadin in a Finnish population with celiac disease. Exp Clin Immunogenet. 1985;2(4):185-190. No prevalence or incidence reported. [pmid: 3917148].
Feighery C. Coeliac disease. Br Med J. 1999;319(7204):236-239. No prevalence or incidence reported. [pmid: 10417090]. [pmcid: 1116331].
Feltkamp T E, Aarden L A, Lucas C J, et al. Genetic risk factors for autoimmune diseases. Immunol Today. 1999;20(1):10-12. No prevalence or incidence reported. [pmid: 10081223].
Ferfoglia G, Pulitano R, Sategna-Guidetti C. Do dietary antibodies still play a role in the diagnosis and follow-up of coeliac disease? A comparison among different serological tests. Panminerva Med. 1995;37(2):55-59. No prevalence or incidence reported. [pmid: 8637769].
Ferguson A, Denton-Miller P, Lai C L. Coeliac disease--objectives of life-long follow-up. Health Bull (Edinb). 1977;35(2):78-80. No prevalence or incidence reported. [pmid: 404272].
Ferguson A, Hutton M M, Maxwell J D, et al. Adult coeliac disease in hyposplenic patients. Lancet. 1970;1(7639):163-164. No prevalence or incidence reported. [pmid: 4189238].
Ferguson A, Kingstone K. Coeliac disease and malignancies. Acta Paediatr. 1996;412(Suppl):78-81. No prevalence or incidence reported.
Ferguson A, Ziegler K, Strobel S. Gluten intolerance (coeliac disease). Ann Allergy. 1984;53(6 Pt 2):637-642. No prevalence or incidence reported. [pmid: 6391293].
Ferguson A. Celiac disease, an eminently treatable condition, may be underdiagnosed in the United States. Am J Gastroenterol. 1997;92(8):1252-1254. Review article. [pmid: 9399743].
Ferguson A. Coeliac disease (gluten hypersensitivity). J Hum Nutr. 1976;30(3):193-201. No prevalence or incidence reported. [pmid: 800225].
Ferguson A. Coeliac disease. Prescr J. 1997;37(4):206-212. No prevalence or incidence reported.
Ferguson A. Immunological functions of the gut in relation to nutritional state and mode of delivery of nutrients. Gut. 1994;35(1 Suppl):S10-S12. No prevalence or incidence reported. [pmid: 8200562]. [pmcid: 1378139].
Fernandez L, Fernandez-Arquero M, Gual L, et al. Triplet repeat polymorphism in the transmembrane region of the MICA gene in celiac disease. Tissue Antigens. 2002;59(3):219-222. No prevalence or incidence reported. [pmid: 12074713].
Fernandez N, Hitman G A, Festenstein H, et al. Novel HLA class II-associated structural patterns in coeliac disease and type I diabetes. Clin Exp Immunol. 1988;72(3):362-366. No prevalence or incidence reported. [pmid: 2901925]. [pmcid: 1541555].
Fernandez-Arquero M, Caldes T, Casado E, et al. Polymorphism within the HLA-DQB1*02 promoter associated with susceptibility to coeliac disease. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1998;25(1):1-3. No prevalence or incidence reported. [pmid: 9587738].
Fernandez-Arquero M, Figueredo M A, Maluenda C, et al. HLA-linked genes acting as additive susceptibility factors in celiac disease. Hum Immunol. 1995;42(4):295-300. No prevalence or incidence reported. [pmid: 7558913].
Fernandez-Arquero M, Polanco I, Escobar H, et al. HLA-DQ alleles and susceptibility to celiac disease in Spanish children. Tissue Antigens. 1995;45(2):145-147. No prevalence or incidence reported. [pmid: 7792763].
Ferrante P, Petronzelli F, Mariani P, et al. Oligotyping of Italian celiac patients with the 11th International Histocompatibility Workshop reagents. Tissue Antigens. 1992;39(1):38-39. No prevalence or incidence reported. [pmid: 1542877].
Festenstein H, Nyulassy S. Workshop on HLA and disease. Transplant Proc. 1979;11(1):1183-1185. No prevalence or incidence reported. [pmid: 313097].
Fickling W E, McFarlane X A, Bhalla A K, et al. The clinical impact of metabolic bone disease in coeliac disease. Postgrad Med J. 2001;77(903):33-36. No prevalence or incidence reported. [pmid: 11123392].
Fine K D, Do K, Schulte K, et al. High prevalence of celiac sprue-like HLA-DQ genes and enteropathy in patients with the microscopic colitis syndrome. Am J Gastroenterol. 2000;95(8):1974-1982. Not a relevant screening group. [pmid: 10950045].
Fine K D, Lee E L, Meyer R L. Colonic histopathology in untreated celiac sprue or refractory sprue: is it lymphocytic colitis or colonic lymphocytosis?. Hum Pathol. 1998;29(12):1433-1440. No prevalence or incidence reported. [pmid: 9865829].
Fine K D, Meyer R L, Lee E L. The prevalence and causes of chronic diarrhea in patients with celiac sprue treated with a gluten-free diet. Gastroenterology. 1997;112(6):1830-1838. No prevalence or incidence reported. [pmid: 9178673].
Fine K D, Ogunji F, Saloum Y, et al. Celiac sprue: another autoimmune syndrome associated with hepatitis C. Am J Gastroenterol. 2001;96(1):138-145. No prevalence or incidence reported. [pmid: 11197243].
Fine K D. The prevalence of occult gastrointestinal bleeding in celiac sprue. N Engl J Med. 1996;334(18):1163-1167. No prevalence or incidence reported. [pmid: 8602182].
Finkel M, Gelb A M, Cohen N, et al. Long-term follow-up study in idiopathic steatorrhea. Am J Gastroenterol. 1967;47(1):35-40. No prevalence or incidence reported. [pmid: 6017662].
Fischer G F, Mayr W R. Molecular genetics of the HLA complex. Wien Klin Wochenschr. 2001;113(2021):814-824. No prevalence or incidence reported. [pmid: 11732117].
Flanders G, Graves P, Rewers M. Prevention of type 1 diabetes from laboratory to public health. Autoimmunity. 1999;29(3):235-246. No prevalence or incidence reported. [pmid: 10433102].
Fleming A F. Iron deficiency in the tropics. Clin Haematol. 1982;11(2):365-388. No prevalence or incidence reported. [pmid: 7042157].
Floreani A, Betterle C, Baragiotta A, et al. Prevalence of coeliac disease in primary biliary cirrhosis and of antimitochondrial antibodies in adult coeliac disease patients in Italy. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(4):258-261. No prevalence or incidence reported. [pmid: 12038809].
Fogg Matthew I, Spergel Jonathan M. Management of food allergies. Expert Opin Pharmacother. 2003;4(7):1025-1037. No prevalence or incidence reported. [pmid: 12831331].
Foldes-Papp Zeno, Demel Ulrike, Berry Desiree, et al. Tissue transglutaminase antibody determination in celiac disease. Analysis of diagnostic specificity of anti-human IgA-type assays. J Immunoassay Immunochem. 2002;23(2):211-227. No prevalence or incidence reported. [pmid: 12033644].
Fotoulaki M, Nousia-Arvanitakis S, Augoustidou-Savvopoulou P, et al. Clinical application of immunological markers as monitoring tests in celiac disease. Dig Dis Sci. 1999;44(10):2133-2138. No prevalence or incidence reported. [pmid: 10548368].
Fox L A. Diabetes therapy in children: Setting age-appropriate goals. Drug Benefit Trends 2002;14(Suppl D):30–35+44. No prevalence or incidence reported
Francis James, Carty John E, Scott Brian B. The prevalence of coeliac disease in rheumatoid arthritis. Eur J Gastroenterol Hepatol. 2002;14(12):1355-1356. No prevalence or incidence reported. [pmid: 12468957].
Frank L, Marian A, Visser M, et al. Exposure to peanuts in utero and in infancy and the development of sensitization to peanut allergens in young children. Pediatr Allergy Immunol. 1999;10(1):27-32. No prevalence or incidence reported. [pmid: 10410914].
Franklin J L, Asquith P, Rosenberg I H. The occurrence of cystic fibrosis and celiac sprue within a single sibship. Am J Dig Dis. 1974;19(2):149-155. No prevalence or incidence reported. [pmid: 4811169].
Fraser J S, Ciclitira P J. Pathogenesis of coeliac disease: Implications for treatment. World J Gastroenterol. 2001;7(6):772-776. No prevalence or incidence reported. [pmid: 11854898].
Fraser J S, Woodhouse N J, El Shafie O T, et al. Occult celiac disease in adult Omanis with unexplained iron deficiency anemia. Saudi Med J. 2003;24(7):791. No prevalence or incidence reported. [pmid: 12883621].
Fraser N G, Ferguson A, Murray D. Dermatitis herpetiformis in two patients with idiopathic steatorrhoea (adult coeliac disease). Br Med J. 1968;3(622):30-31. No prevalence or incidence reported. [pmid: 5677213].
Freeman H J. Biopsy-defined adult celiac disease in Asian-Canadians. Can J Gastroenterol. 2003;17(7):433-436. No prevalence or incidence reported. [pmid: 14679418].
Freeman H J. Failure of added dietary gluten to induce small intestinal histopathological changes in patients with watery diarrhea and lymphocytic colitis. Can J Gastroenterol. 1996;10(7):436-439. No prevalence or incidence reported. [pmid: 9113886].
Freeman H J. Free perforation due to intestinal lymphoma in biopsy-defined or suspected celiac disease. J Clin Gastroenterol. 2003;37(4):299-302. No prevalence or incidence reported. [pmid: 14506386].
Freeman H J. Hepatobiliary tract and pancreatic disorders in celiac disease. Can J Gastroenterol. 1997;11(1):77-81. No prevalence or incidence reported. [pmid: 9459049].
Freeman H J. Neoplastic disorders in 100 patients with adult celiac disease. Can J Gastroenterol. 1996;10(3):163-166. No prevalence or incidence reported. [pmid: 9113886].
Freeman H J. Solid-phase ELISA for tissue transglutaminase, an endomysial target for possible serological diagnosis of celiac disease. Can J Gastroenterol. 1998;12(5):323-324. No prevalence or incidence reported. [pmid: 10206732].
Freeman H J. Survey of gastroenterologists on the diagnosis and treatment of adult patients with celiac disease in British Columbia. Can J Gastroenterol. 1998;12(2):149-152. No prevalence or incidence reported. [pmid: 10206732].
Freemark M, Levitsky L L. Screening for celiac disease in children with type 1 diabetes: Two views of the controversy. Diabetes Care. 2003;26(6):1932-1939. No prevalence or incidence reported. [pmid: 12766138].
Freier S. Paediatric gastrointestinal allergy. Clin Allergy. 1973;3(Suppl):597-618. No prevalence or incidence reported. [pmid: 4620910].
Frezal J, Rey J. Genetics of disorders of intestinal digestion and absorption. Adv Hum Genet 1970;1275–336. No prevalence or incidence reported
Fric P, Lojda Z, Jodl J, et al. Analysis of peroral jejunal biopsies in clinically asymptomatic parents of children with celiac sprue. Digestion. 1969;2(1):35-42. Not a relevant screening geography. [pmid: 5776465].
Fried M W. Side effects of therapy of hepatitis C and their management. J Gastroenterol Hepatol. 2002;36(5 I):S237-S244. No prevalence or incidence reported. [pmid: 11982722].
Friis S U, Gudmand-Hoyer E. Screening for coeliac disease in adults by simultaneous determination of IgA and IgG gliadin antibodies. Scand J Gastroenterol. 1986;21(9):1058-1062. No prevalence or incidence reported. [pmid: 3810005].
Frisoni G B, Carabellese N, Longhi M, et al. Is celiac disease associated with Alzheimer's disease?. Acta Neurol Scand. 1997;95(3):147-151. No prevalence or incidence reported. [pmid: 9088382].
Frustaci Andrea, Cuoco Lucio, Chimenti Cristina, et al. Celiac disease associated with autoimmune myocarditis. Circulation. 2002;105(22):2611-2618. No prevalence or incidence reported. [pmid: 12045166].
Fry L, Seah P P, Hoffbrand A V. Dermatitis herpetiformis. Clin Gastroenterol. 1974;3(1):145-157. No prevalence or incidence reported. [pmid: 4599262].
Fry L, Seah P P, Riches D J, et al. Clearance of skin lesions in dermatitis herpetiformis after gluten withdrawal. Lancet. 1973;1(7798):288-291. No prevalence or incidence reported. [pmid: 4119171].
Fry L. Dermatitis herpetiformis. Bailliere's Clin Gastroenterol. 1995;9(2):371-393. No prevalence or incidence reported. [pmid: 7549032].
Fry Lionel. Dermatitis herpetiformis: problems, progress and prospects. European Journal of Dermatology - Ejd. 2002;12(6):523-531. No prevalence or incidence reported. [pmid: 12459520].
Fundia A F, Gonzalez Cid M B, Bai J, et al. Chromosome instability in lymphocytes from patients with celiac disease. Clin Genet. 1994;45(2):57-61. No prevalence or incidence reported. [pmid: 8004798].
Fundia A, Gomez J C, Maurino E, et al. Chromosome instability in untreated adult celiac disease patients. Acta Paediatr. 1996;412(Suppl):82-84. No prevalence or incidence reported.
Gabrielli Maurizio, Cremonini Filippo, Fiore Giuseppe, et al. Association between migraine and Celiac disease: results from a preliminary case-control and therapeutic study. Am J Gastroenterol. 2003;98(3):625-629. No prevalence or incidence reported. [pmid: 12650798].
Gale J, Simmonds P D, Mead G M, et al. Enteropathy-type intestinal T-cell lymphoma: clinical features and treatment of 31 patients in a single center. Journal of Clinical Oncology - Official Journal of the American Society of Clinical Oncology. 2000;18(4):795-803. No prevalence or incidence reported. [pmid: 10673521].
Gale L, Wimalaratna H, Brotodiharjo A, et al. Down Syndrome is strongly associated with coeliac disease. Gut. 1997;40(4):492-496. Not a relevant screening group. [pmid: 9176077]. [pmcid: 1027124].
Galli-Tsinopoulou A, Nousia-Arvanitakis S, Dracoulacos D, et al. Autoantibodies predicting diabetes mellitus type I in celiac disease. Horm Res. 1999;52(3):119-124. No prevalence or incidence reported. [pmid: 10725775].
Gandolfi L, Pratesi R, Cordoba J C, et al. Prevalence of celiac disease among blood donors in Brazil. Am J Gastroenterol. 2000;95(3):689-692. Not a relevant screening geography. [pmid: 10710058].
Gans R O B, Ueda Y, Ito S, et al. The occurrence of IgA-nephropathy in patients with diabetes mellitus may not be coincidental: A report of five cases. Am J Kidney Dis. 1992;20(3):255-260. No prevalence or incidence reported. [pmid: 1519606].
Garces M C, Gomez-Cerezo J, Codoceo R, et al. Postprandial cholecystokinin response in patients with chronic pancreatitis in treatment with oral substitutive pancreatic enzymes. Dig Dis Sci. 1998;43(3):562-566. No prevalence or incidence reported. [pmid: 9539652].
Garcia Vilela E, De Lourdes, de Abreu, et al. Agreement between pathologists concerning assessment of intestinal biopsies from adult celiac disease patients. Gastroenterol Int. 2002;15(12):1-8. No prevalence or incidence reported.
Gardiner A J, Mutton K J, Walker-Smith J A. A family study of coeliac disease. Aust Paediatr J. 1973;9(1):18-24. Not a relevant screening geography. [pmid: 4740140].
Gardiner A, Porteous N, Walker-Smith J A. The effect of coeliac disease on the mother-child relationship. Aust Paediatr J. 1972;8(1):39-43. No prevalence or incidence reported. [pmid: 5045509].
Garioch J J, Lewis H M, Sargent S A, et al. 25 years' experience of a gluten-free diet in the treatment of dermatitis herpetiformis. Br J Dermatol. 1994;131(4):541-545. No prevalence or incidence reported. [pmid: 7947207].
Garioch J J. Dermatitis herpetiformis and its management. Prescr J. 1996;36(3):141-145. No prevalence or incidence reported.
Garn S M, Poznanski A K, Nagy J M. Bone measurement in the differential diagnosis of osteopenia and osteoporosis. Radiology. 1971;100(3):509-518. No prevalence or incidence reported. [pmid: 4254881].
Garrote J A, Sorell L, Alfonso P, et al. A novel visual immunoassay for coeliac disease screening. Eur J Clin Invest. 1999;29(8):697-699. No prevalence or incidence reported. [pmid: 10457154].
Garrote Jose A, Arranz Eduardo, Telleria Juan J, et al. TNF alpha and LT alpha gene polymorphisms as additional markers of celiac disease susceptibility in a DQ2-positive population. Immunogenetics. 2002;54(8):551-555. No prevalence or incidence reported. [pmid: 12439617].
Gasbarrini A, Ojetti V, Cuoco L, et al. Lack of endoscopic visualization of intestinal villi with the “immersion technique” in overt atrophic celiac disease. Gastrointest Endosc. 2003;57(3):348-351. No prevalence or incidence reported. [pmid: 12612514].
Gasbarrini G, Ciccocioppo R, De Vitis I, et al. Coeliac Disease in the Elderly. A multicentre Italian study. Gerontology. 2001;47(6):306-310. No prevalence or incidence reported. [pmid: 11721143].
Gastard J, Joubaud F, Farbos T, et al. Etiology and course of primary chronic pancreatitis in Western France. Digestion. 1973;9(5):416-428. No prevalence or incidence reported. [pmid: 4784703].
Gautrin D, Ghezzo H, Infante-Rivard C, et al. Incidence and host determinants of work-related rhinoconjunctivitis in apprentice pastry-makers. Allergy Eur J Allergy Clin Immunol. 2002;57(10):913-918. No prevalence or incidence reported.
Gawkrodger D J, Blackwell J N, Gilmour H M, et al. Dermatitis herpetiformis: diagnosis, diet and demography. Gut. 1984;25(2):151-157. No prevalence or incidence reported. [pmid: 6693042]. [pmcid: 1432259].
Gay G J, Delmotte J S. Enteroscopy in small intestinal inflammatory diseases. Gastrointest Endosc Clin N Am. 1999;9(1):115-123. No prevalence or incidence reported. [pmid: 9834320].
Gayer G, Apter S, Hofmann C, et al. Intussusception in adults: CT diagnosis. Clin Radiol. 1998;53(1):53-57. No prevalence or incidence reported. [pmid: 9464437].
Gazet J C, Pilkington T R, Kalucy R S, et al. Treatment of gross obesity by jejunal bypass. Br Med J. 1974;4(5940):311-314. No prevalence or incidence reported. [pmid: 4434086]. [pmcid: 1612920].
Gazit E, Avigad S, Zfat Z, et al. The association of HL-A-B8 and childhood celiac disease in an Israeli population. Isr J Med Sci. 1977;13(4):400-404. No prevalence or incidence reported. [pmid: 873760].
Gebhard R L, Katz S I, Marks J, et al. HL-A antigen type and small-intestinal disease in dermatitis herpetiformis. Lancet. 1973;2(7832):760-762. No prevalence or incidence reported. [pmid: 4126478].
Gemme G, Vignolo M, Naselli A, et al. Linear growth and skeletal maturation in subjects with treated celiac disease. J Pediatr Gastroenterol Nutr. 1999;29(3):339-342. No prevalence or incidence reported. [pmid: 10468002].
George E K, Hertzberger-ten Cate R, Suijlekom-Smit L W, et al. Juvenile chronic arthritis and coeliac disease in The Netherlands. Clin Exp Rheumatol. 1996;14(5):571-575. No prevalence or incidence reported. [pmid: 8913663].
George E K, Jansen T L, Mearin M L, et al. Epidemiology of celiac disease in The Netherlands. J Pediatr Gastroenterol Nutr. 1997;24(5):S7-S9. Not a relevant screening test. [pmid: 9161967].
George E K, Mearin M L, Bouquet J, et al. High frequency of celiac disease in Down syndrome. Eur J Pediatr. 1996;128(4):555-557. No prevalence or incidence reported.
George E K, Mearin M L, Bouquet J, et al. Screening for coeliac disease in Dutch children with associated diseases. Acta Paediatr. 1996;412(Suppl):52-53. No prevalence or incidence reported.
George E K, Mearin M L, Franken H C, et al. Twenty years of childhood coeliac disease in The Netherlands: a rapidly increasing incidence?. Gut. 1997;40(1):61-66. Serology screen <1990. [pmid: 9155577]. [pmcid: 1027009].
George E K, Mearin M L, van der V, et al. Low incidence of childhood celiac disease in The Netherlands. Pediatr Res. 1995;37(2):213-218. Serology screen <1990. [pmid: 7731760].
Gheorghe L, Gheorghe C, Aposteanu G, et al. Clinical spectrum of adult celiac disease in a referral center for Southern Romania. Associated disorders and short-term survival. Rom J Gastroenterol. 1996;5(4):223-228. No prevalence or incidence reported.
Ghezzi A, Zaffaroni M. Neurological manifestations of gastrointestinal disorders, with particular reference to the differential diagnosis of multiple sclerosis. Neurol Sci. 2002;22(Suppl 2):S117-S122. No prevalence or incidence reported.
Ghosh S K, Littlewood J M, Goddard D, et al. Stool microscopy in screening for steatorrhoea. J Clin Pathol. 1977;30(8):749-753. No prevalence or incidence reported. [pmid: 599187]. [pmcid: 476539].
Giampietro P G, Ragno V, Daniele S, et al. Soy hypersensitivity in children with food allergy. Ann Allergy. 1992;69(2):143-146. No prevalence or incidence reported. [pmid: 1380784].
Giannotti A, Tiberio G, Castro M, et al. Coeliac disease in Williams syndrome. J Med Genet. 2001;38(11):767-768. No prevalence or incidence reported. [pmid: 11694549].
Giardiello F M, Lazenby A J. The atypical colitides. Gastroenterol Clin North Am. 1999;28(2):479-490. No prevalence or incidence reported. [pmid: 10372278].
Gilett H R, Freeman H J. Prevalence of celiac disease in collagenous and lymphocytic colitis. Can J Gastroenterol. 2000;14(11):919-921. No prevalence or incidence reported. [pmid: 11125181].
Gilett P M, Gilett H R, Israel D M, et al. Increased prevalence of celiac disease in girls with Turner syndrome detected using antibodies to endomysium and tissue transglutaminase. Can J Gastroenterol. 2000;14(11):915-918. No prevalence or incidence reported. [pmid: 11125180].
Gill S S, Heuman D M, Mihas A A. Small intestinal neoplasms. J Clin Gastroenterol. 2001;33(4):267-282. No prevalence or incidence reported. [pmid: 11588539].
Gillberg R, Ahren C. Coeliac disease diagnosed by means of duodenoscopy and endoscopic duodenal biopsy. Scand J Gastroenterol. 1977;12(8):911-916. No prevalence or incidence reported. [pmid: 605350].
Gillet H, Ferguson A, Frier B. Coeliac disease often co-exists with Type 1 diabetes mellitus. Pract Diabetes Int. 1998;15(4):117-120. No prevalence or incidence reported.
Gillett H R, Cauch-Dudek K, Jenny E, et al. Prevalence of IgA antibodies to endomysium and tissue transglutaminase in primary biliary cirrhosis. Can J Gastroenterol. 2000;14(8):672-675. No prevalence or incidence reported. [pmid: 11185531].
Gillett H R, Freeman H J. Comparison of IgA endomysium antibody and IgA tissue transglutaminase antibody in celiac disease. Can J Gastroenterol. 2000;14(8):668-671. No prevalence or incidence reported. [pmid: 11185531].
Gillett H R, Freeman H J. Prevalence of celiac disease in collagenous and lymphocytic colitis. Can J Gastroenterol. 2000;14(11):919-921. No prevalence or incidence reported. [pmid: 11185531].
Gillett H R, Freeman H J. Serological testing in screening for adult celiac disease. Can J Gastroenterol. 1999;13(3):265-269. No prevalence or incidence reported. [pmid: 10331939].
Gillett P M, Gillett H R, Israel D M, et al. Increased prevalence of celiac disease in girls with Turner syndrome detected using antibodies to endomysium and tissue transglutaminase. Can J Gastroenterol. 2000;14(11):915-918. No prevalence or incidence reported. [pmid: 11125180].
Ginzberg H, Shin J, Ellis L, et al. Shwachman syndrome: phenotypic manifestations of sibling sets and isolated cases in a large patient cohort are similar. Eur J Pediatr. 1999;135(1):81-88. No prevalence or incidence reported.
Giordano M, Bolognesi E, D'Alfonso S, et al. Linkage disequilibrium between intra-locus variants in the aminopeptidase n gene and test of their association with coeliac disease. Ann Hum Genet. 1999;63(Pt 3):207-215. No prevalence or incidence reported. [pmid: 10738533].
Giovagnorio F, Picarelli A, Di Giovambattista F, et al. Evaluation with Doppler sonography of mesenteric blood flow in celiac disease. Ajr. American Journal of Roentgenology. 1998;171(3):629-632. No prevalence or incidence reported. [pmid: 9725286].
Giusti Judy. What you should know about celiac disease. Diabetes Self Manag 2003;20(1):66, 68–69, 71. No prevalence or incidence reported
Gobbi G, Bouquet F, Greco L, et al. Coeliac disease, epilepsy, and cerebral calcifications. The Italian Working Group on Coeliac Disease and Epilepsy. Lancet. 1992;340(8817):439-443. No prevalence or incidence reported. [pmid: 1354781].
Godkin A, Friede T, Davenport M, et al. Use of eluted peptide sequence data to identify the binding characteristics of peptides to the insulin-dependent diabetes susceptibility allele HLA-DQ8 (DQ 3.2). Int Immunol. 1997;9(6):905-911. No prevalence or incidence reported. [pmid: 9199974].
Goggins M, Kelleher D. Celiac disease and other nutrient related injuries to the gastrointestinal tract. Am J Gastroenterol. 1994;89(8 Suppl):S2-17. No prevalence or incidence reported. [pmid: 8048412].
Goldberg D P. A one-year survey of the prevalence of psychiatric illness in patients with disease of the small intestine. Gut. 1968;9(6):725. No prevalence or incidence reported. [pmid: 5717976]. [pmcid: 1552892].
Goldberg D. A psychiatric study of patients with diseases of the small intestine. Gut. 1970;11(6):459-465. No prevalence or incidence reported. [pmid: 5485836]. [pmcid: 1553040].
Golden M H. Is complete catch-up possible for stunted malnourished children?. Eur J Clin Nutr 1994;48(Suppl 1):s58–s70; Discussion S71. No prevalence or incidence reported
Gomez J C, Selvaggio G S, Viola M, et al. Prevalence of celiac disease in Argentina: screening of an adult population in the La Plata area. Am J Gastroenterol. 2001;96(9):2700-2704. Not a relevant screening geography. [pmid: 11569698].
Gomez Juan C, Selvaggio Gisella, Pizarro Bibiana, et al. Value of a screening algorithm for celiac disease using tissue transglutaminase antibodies as first level in a population-based study. Am J Gastroenterol. 2002;97(11):2785-2790. Not a relevant screening geography. [pmid: 12425549].
Gonzalez D, Mazure R, Mautalen C, et al. Body composition and bone mineral density in untreated and treated patients with celiac disease. Bone. 1995;16(2):231-234. No prevalence or incidence reported. [pmid: 7756052].
Goodchild M C, Nelson R, Anderson C M. Cystic fibrosis and coeliac disease: coexistence in two children. Arch Dis Child. 1973;48(9):684-691. No prevalence or incidence reported. [pmid: 4517654].
Goodwin M S, Goodwin T C. In a dark mirror. Ment Hyg. 1969;53(4):550-563. No prevalence or incidence reported. [pmid: 4242008].
Gordon N. Cerebellar ataxia and gluten sensitivity: a rare but possible cause of ataxia, even in childhood. Dev Med Child Neurol. 2000;42(4):283-286. No prevalence or incidence reported. [pmid: 10755462].
Gorski J, Niven M J, Sachs J A, et al. HLA-DR alpha, - DX alpha, and DR beta III gene association studies in DR3 individuals. Hum Immunol. 1987;20(4):273-278. No prevalence or incidence reported. [pmid: 2893780].
Goswami R, Tandon R K, Dudha A, et al. Prevalence and significance of steatorrhea in patients with active Graves' disease. Am J Gastroenterol. 1998;93(7):1122-1125. No prevalence or incidence reported. [pmid: 9672342].
Goulet O, Kedinger M, Brousse N, et al. Intractable diarrhea of infancy with epithelial and basement membrane abnormalities. Eur J Pediatr. 1995;127(2):212-219. No prevalence or incidence reported.
Gourtsoyiannis N C, Nolan D J. Lymphoma of the small intestine: radiological appearances. Clin Radiol. 1988;39(6):639-645. No prevalence or incidence reported. [pmid: 3243056].
Granot E, Korman S M, Sallon S, et al. “Early” vs. “late” diagnosis of celiac disease in two ethnic groups living in the same geographic area. Isr J Med Sci. 1994;30(4):271-275. No prevalence or incidence reported. [pmid: 8175328].
Greco L, Auricchio S, Mayer M, et al. Case control study on nutritional risk factors in celiac disease. J Pediatr Gastroenterol Nutr. 1988;7(3):395-399. No prevalence or incidence reported. [pmid: 3385552].
Greco L, Babron M C, Corazza G R, et al. Existence of a genetic risk factor on chromosome 5q in Italian coeliac disease families. Ann Hum Genet. 2001;65(Pt 1):35-41. No prevalence or incidence reported. [pmid: 11415521].
Greco L, Corazza G, Babron M C, et al. Genome search in celiac disease. Am J Hum Genet. 1998;62(3):669-675. No prevalence or incidence reported. [pmid: 9497251]. [pmcid: 1376948].
Greco L, De Seta L, D'Adamo G, et al. Atopy and coeliac disease: bias or true relation?. Acta Paediatr Scand. 1990;79(67):670-674. No prevalence or incidence reported. [pmid: 2386060].
Greco L, Mayer M, Ciccarelli G, et al. Compliance to a gluten-free diet in adolescents, or “what do 300 coeliac adolescents eat every day?”. Ital J Gastroenterol Hepatol. 1997;29(4):305-310. No prevalence or incidence reported. [pmid: 9476181].
Greco L, Percopo S, Clot F, et al. Lack of correlation between genotype and phenotype in celiac disease. J Pediatr Gastroenterol Nutr. 1998;26(3):286-290. No prevalence or incidence reported. [pmid: 9523863].
Greco L, Percopo S. The coeliac disease task force “ Free from Gluten,” “ Improved knowledge to cure coeliac disease”. Acta Paediatr. 1996;412(Suppl):25-28. No prevalence or incidence reported.
Greco L, Romino R, Coto I, et al. The first large population based twin study of coeliac disease. Gut. 2002;50(5):624-628. No prevalence or incidence reported. [pmid: 11950806]. [pmcid: 1773191].
Greco L, Tipo V, Di Donato F, et al. Pulsatile growth pattern during catch-up growth in childhood coeliac disease. Acta Paediatr. 1994;83(7):724-729. No prevalence or incidence reported. [pmid: 7949802].
Greco L, Tozzi A E, Mayer M, et al. Unchanging clinical picture of coeliac disease presentation in Campania, Italy. Eur J Pediatr. 1989;148(7):610-613. No prevalence or incidence reported. [pmid: 2744033].
Greco L, Troncone R. Coeliac families. Acta Paediatr. 2002;91(1):16-17. No prevalence or incidence reported. [pmid: 11883812].
Green P H R, Jabri B. Celiac disease and other precursors to small-bowel malignancy. Gastroenterol Clin North Am. 2002;31(2):625-639. No prevalence or incidence reported. [pmid: 12134621].
Green P H R, Stavropoulos S N, Panagi S G, et al. Characteristics of adult celiac disease in the USA: results of a national survey. Am J Gastroenterol. 2001;96(1):126-131. No prevalence or incidence reported. [pmid: 11197241].
Green Peter H R, Fleischauer Aaron T, Bhagat Govind, et al. Risk of malignancy in patients with celiac disease. Am J Med. 2003;115(3):191-195. No prevalence or incidence reported. [pmid: 12935825].
Green Peter H R, Jabri Bana. Coeliac disease. Lancet. 2003;362(9381):383-391. No prevalence or incidence reported. [pmid: 14615111].
Green R, Luyt D. Clinical characteristics of childhood asthmatics in Johannesburg. S Afr Med J. 1997;87(7):878-882. No prevalence or incidence reported. [pmid: 9323404].
Greenberg D A, Hodge S E, Rotter J I. Evidence for recessive and against dominant inheritance at the HLA-“linked” locus in coeliac disease. Am J Hum Genet. 1982;34(2):263-277. No prevalence or incidence reported. [pmid: 6951410]. [pmcid: 1685281].
Greenberg D A, Rotter J I. Two locus models for gluten sensitive enteropathy: population genetic considerations. Am J Med Genet. 1981;8(2):205-214. No prevalence or incidence reported. [pmid: 7282774].
Greenberger N J. Update in gastroenterology. Ann Intern Med. 1999;131(6):445-452. No prevalence or incidence reported. [pmid: 10498562].
Grigg A P, Angus P W, Hoyt R, et al. The incidence, pathogenesis and natural history of steatorrhea after bone marrow transplantation. Bone Marrow Transplant. 2003;31(8):701-703. No prevalence or incidence reported. [pmid: 12728924].
Grillo R, Petronzelli F, Mora B, et al. Search for coeliac disease susceptibility loci on 7q11.23 candidate region: absence of association with the ELN17 microsatellite marker. Hum Hered. 2000;50(3):180-183. No prevalence or incidence reported. [pmid: 10686497].
Grodzinsky E, Hed J, Skogh T. IgA antiendomysium antibodies have a high positive predictive value for celiac disease in asymptomatic patients. Allergy. 1994;49(8):593-597. No prevalence or incidence reported. [pmid: 7653735].
Groisman G M, Amar M, Livne E. CD10: A valuable tool for the light microscopic diagnosis of microvillous inclusion disease (familial microvillous atrophy). Am J Surg Pathol. 2002;26(7):902-907. No prevalence or incidence reported. [pmid: 12131157].
Groll A, Candy D C, Preece M A, et al. Short stature as the primary manifestation of coeliac disease. Lancet. 1980;2(8204):1097-1099. No prevalence or incidence reported. [pmid: 6107721].
Gruskay F L. Comparison of breast, cow, and soy feedings in the prevention of onset of allergic disease. A 15-year prospective study. Clin Pediatr. 1982;21(8):486-491. No prevalence or incidence reported.
Guandalini S. Celiac disease in the new world. J Pediatr Gastroenterol Nutr. 2000;31(4):362-364. No prevalence or incidence reported. [pmid: 11045848].
Guandalini Stefano. Celiac disease. School Nurse News. 2003;20(2):24-27. No prevalence or incidence reported. [pmid: 12683313].
Guarino A, Spagnuolo M I, Russo S, et al. Etiology and risk factors of severe and protracted diarrhea. J Pediatr Gastroenterol Nutr. 1995;20(2):173-178. No prevalence or incidence reported. [pmid: 7714682].
Gudmand-Hoyer E. The clinical significance of disaccharide maldigestion. Am J Clin Nutr. 1994;59(3 Suppl):735s-741s. No prevalence or incidence reported. [pmid: 8116558].
Guglielmino C R, De Silvestri A, Martinetti M. HLA class I and II genes in relation to the genetic structure and epidemiology of an Italian province. Exp Clin Immunogenet. 1997;14(2):149-159. No prevalence or incidence reported. [pmid: 9395891].
Gumaa S N, McNicholl B, Egan-Mitchell B, et al. Coeliac disease in Galway, Ireland 1971-1990. Ir Med J. 1997;90(2):60-61. Serology screen <1990. [pmid: 9105127].
Gupte S. Changing concepts in celiac disease. Jk Science. 2001;3(3):103-104. No prevalence or incidence reported.
Gutteridge D H, Robinson C J, Joplin G F. Delayed strontium absorption in post-menopausal osteoporosis and osteomalacia. Clin Sci. 1968;34(2):351-363. No prevalence or incidence reported. [pmid: 5653693].
Guvenc cedil, Kaymakog caron, Gurel N, et al. The prevalence of manifest and latent celiac disease in type 1 diabetes mellitus. Turk J Gastroenterol. 2002;13(2):103-107. Not a relevant screening geography. [pmid: 16378286].
Haaber A B, Rosenfalck A M, Hansen B, et al. Bone mineral metabolism, bone mineral density, and body composition in patients with chronic pancreatitis and pancreatic exocrine insufficiency. International Journal of Pancreatology - Official Journal of the International Association of Pancreatology. 2000;27(1):21-27. No prevalence or incidence reported. [pmid: 10811020].
Habior Andrzej, Lewartowska Aleksandra, Orlowska Janina, et al. Association of coeliac disease with primary biliary cirrhosis in Poland. Eur J Gastroenterol Hepatol. 2003;15(2):159-164. No prevalence or incidence reported. [pmid: 12560760].
Hadjivassiliou M, Davies-Jones G A B, Sanders D S, et al. Dietary treatment of gluten ataxia. J Neurol Neurosurg Psychiatry. 2003;74(9):1221-1224. No prevalence or incidence reported. [pmid: 12933922].
Hadjivassiliou M, Gibson A, Davies-Jones G A, et al. Does cryptic gluten sensitivity play a part in neurological illness?. Lancet. 1996;347(8998):369-371. No prevalence or incidence reported. [pmid: 8598704].
Hadjivassiliou M, Grunewald R A, Chattopadhyay A K, et al. Clinical, radiological, neurophysiological, and neuropathological characteristics of gluten ataxia. Lancet. 1998;352(9140):1582-1585. No prevalence or incidence reported. [pmid: 9843103].
Hadjivassiliou M, Grunewald R A, Davies-Jones G A B. Gluten sensitivity as a neurological illness. J Neurol Neurosurg Psychiatry. 2002;72(5):560-563. No prevalence or incidence reported. [pmid: 11971034].
Hadjivassiliou Marios, Grunewald Richard, Sharrack Basil, et al. Gluten ataxia in perspective: epidemiology, genetic susceptibility and clinical characteristics. Brain Dev. 2003;126(Pt 3):685-691. No prevalence or incidence reported.
Hadziselimovic F, Emmons L R, Schaub U, et al. Occurrence of large granular lymphocytes and natural killer cells in the epithelium of the gut distinguishes two different coeliac diseases. Gut. 1992;33(6):767-772. No prevalence or incidence reported. [pmid: 1624157]. [pmcid: 1379333].
Haeney M R, Goodwin B J, Barratt M E, et al. Soya protein antibodies in man: their occurrence and possible relevance in coeliac disease. J Clin Pathol. 1982;35(3):319-322. No prevalence or incidence reported. [pmid: 7040491]. [pmcid: 497538].
Hagan L L, Goetz D W, Revercomb C H, et al. Sudden infant death syndrome: A search for allergen hypersensitivity. Ann Allergy Asthma Immunol. 1998;80(3):227-231. No prevalence or incidence reported. [pmid: 9532970].
Hakanen M, Luotola K, Salmi J, et al. Clinical and subclinical autoimmune thyroid disease in adult celiac disease. Dig Dis Sci. 2001;46(12):2631-2635. No prevalence or incidence reported. [pmid: 11768252].
Hakeem V, Fifield R, al Bayaty H F, et al. Salivary IgA antigliadin antibody as a marker for coeliac disease. Arch Dis Child. 1992;67(6):724-727. No prevalence or incidence reported. [pmid: 1626993].
Hall R P, Clark R E, Ward F E. Dermatitis herpetiformis in two American blacks: HLA type and clinical characteristics. J Am Acad Dermatol. 1990;22(3):436-439. No prevalence or incidence reported. [pmid: 2312829].
Hall R P, Owen S, Smith A, et al. TCR Vbeta expression in the small bowel of patients with dermatitis herpetiformis and gluten sensitive enteropathy. Limited expression in dermatitis herpetiformis and treated asymptomatic gluten sensitive enteropathy. Exp Dermatol. 2000;9(4):275-282. No prevalence or incidence reported. [pmid: 10949550].
Hall R P, Ward F E, Wenstrup R J. An HLA class II region restriction fragment length polymorphism (RFLP) in patients with dermatitis herpetiformis: association with HLA-DP phenotype. J Invest Dermatol. 1990;95(2):172-177. No prevalence or incidence reported. [pmid: 1974277].
Hallert C, Astrom J. Intellectual ability of adults after lifelong intestinal malabsorption due to coeliac disease. J Neurol Neurosurg Psychiatry. 1983;46(1):87-89. No prevalence or incidence reported. [pmid: 6842207].
Hallert C, Gotthard R, Jansson G, et al. Similar prevalence of coeliac disease in children and middle-aged adults in a district of Sweden. Gut. 1983;24(5):389-391. No prevalence or incidence reported. [pmid: 6840611]. [pmcid: 1419980].
Hallert C, Gotthard R, Norrby K, et al. On the prevalence of adult coeliac disease in Sweden. Scand J Gastroenterol. 1981;16(2):257-261. Serology screen <1990. [pmid: 7313537].
Hallert C, Granno C, Grant C, et al. Quality of life of adult coeliac patients treated for 10 years. Scand J Gastroenterol. 1998;33(9):933-938. No prevalence or incidence reported. [pmid: 9759948].
Hallert C, Granno C, Hulten S, et al. Living with coeliac disease: controlled study of the burden of illness. Scand J Gastroenterol. 2002;37(1):39-42. No prevalence or incidence reported. [pmid: 11843033].
Hallert C, Grant C, Grehn S, et al. Evidence of poor vitamin status in coeliac patients on a gluten-free diet for 10 years. Aliment Pharmacol Ther. 2002;16(7):1333-1339. No prevalence or incidence reported. [pmid: 12144584].
Hallert C, Lohiniemi S. Quality of life of celiac patients living on a gluten-free diet. Nutrition. 1999;15(10):795-797. No prevalence or incidence reported. [pmid: 10501298].
Halme L, Mecklin J P, Juhola M, et al. Primary gastrointestinal non-Hodgkin's lymphoma. A population based study in central Finland in 1975-1993. Acta Oncol. 1997;36(1):69-74. No prevalence or incidence reported. [pmid: 9090970].
Halsted C H, Rowe J W. Occurrence of celiac sprue in a patient with Fabry's disease. Ann Intern Med. 1975;83(4):524-525. No prevalence or incidence reported. [pmid: 810052].
Hamilton J R, McNeill L K. Childhood celiac disease: response of treated patients to a small uniform daily dose of wheat gluten. Eur J Pediatr. 1972;81(5):885-893. No prevalence or incidence reported.
Hansen T, Ronningen K S, Ploski R, et al. Coding region polymorphisms of human T-cell receptor Vbeta6.9 and Vbeta21.4. Scand J Immunol. 1992;36(2):285-290. No prevalence or incidence reported. [pmid: 1386940].
Hanson L A, Korotkova M, Haversen L, et al. Breast-feeding, a complex support system for the offspring. Pediatr Int. 2002;44(4):347-352. No prevalence or incidence reported. [pmid: 12139555].
Hanson L A. Human milk and host defence: immediate and long-term effects. Acta Paediatrica (Oslo, Norway - 1992). Supplement. 1999;88(430):42-46. No prevalence or incidence reported.
Hansson T, Anneren G, Sjoberg O, et al. Celiac disease in relation to immunologic serum markers, trace elements, and HLA-DR and DQ antigens in Swedish children with Down syndrome. J Pediatr Gastroenterol Nutr. 1999;29(3):286-292. No prevalence or incidence reported. [pmid: 10467993].
Hansson T, Dahlbom I, Hall J, et al. Antibody reactivity against human and guinea pig tissue transglutaminase in children with celiac disease. J Pediatr Gastroenterol Nutr. 2000;30(4):379-384. No prevalence or incidence reported. [pmid: 10776947].
Hansson T, Dannaeus A, Kraaz W, et al. Production of antibodies to gliadin by peripheral blood lymphocytes in children with celiac disease: the use of an enzyme-linked immunospot technique for screening and follow-up. Pediatr Res. 1997;41(4 Pt 1):554-559. No prevalence or incidence reported. [pmid: 9098859].
Hansson T, Ulfgren A-K, Lindroos E, et al. Transforming growth factor-beta (TGF-beta) and tissue transglutaminase expression in the small intestine in children with coeliac disease. Scand J Immunol. 2002;56(5):530-537. No prevalence or incidence reported. [pmid: 12410804].
Hansson Tony, Dahlbom Ingrid, Rogberg Siv, et al. Recombinant human tissue transglutaminase for diagnosis and follow-up of childhood coeliac disease. Pediatr Res. 2002;51(6):700-705. No prevalence or incidence reported. [pmid: 12032264].
Hanukoglu A, Mizrachi A, Dalal I, et al. Extrapancreatic autoimmune manifestations in type 1 diabetes patients and their first-degree relatives: A multicenter study. Diabetes Care. 2003;26(4):1235-1240. No prevalence or incidence reported. [pmid: 12663603].
Harris O D, Cooke W T, Thompson H, et al. Malignancy in adult coeliac disease and idiopathic steatorrhoea. Am J Med. 1967;42(6):899-912. No prevalence or incidence reported. [pmid: 5338480].
Harris O D, Warner M, Cooke W T. Serum alkaline phosphatase in adult coeliac disease. Gut. 1969;10(11):951. No prevalence or incidence reported. [pmid: 5358593].
Harrison J E, McNeill K G, Wilson D R, et al. An evaluation of isotopic calcium absorption tests. Clin Biochem. 1973;6(4):237-245. No prevalence or incidence reported. [pmid: 4798239].
Harrison L C, Honeyman M C. Cow's milk and type 1 diabetes: The real debate is about mucosal immune function. Diabetes. 1999;48(8):1501-1507. No prevalence or incidence reported. [pmid: 10426365].
Hartman C, Hochberg Z, Shamir R. Osteoporosis in pediatrics. Isr Med Assoc J. 2003;5(7):509-515. No prevalence or incidence reported. [pmid: 12901249].
Haslam N, Lock R J, Unsworth D J. Coeliac disease, anaemia and pregnancy. Clin Lab. 2001;47(910):467-469. No prevalence or incidence reported. [pmid: 11596908].
Haslam N, Probert C S. An audit of the investigation and treatment of folic acid deficiency. J R Soc Med. 1998;91(2):72-73. No prevalence or incidence reported. [pmid: 9602741]. [pmcid: 1296488].
Hasler William L. Celiac sprue as a possible cause of symptoms in presumed irritable bowel syndrome. Gastroenterology. 2002;122(7):2086-2087. No prevalence or incidence reported. [pmid: 12078669].
Hattevig G, Kjellman B, Fallstrom S P. Congenital permanent diabetes mellitus and celiac disease. Eur J Pediatr. 1982;101(6):955-957. No prevalence or incidence reported.
Haugen M A, Kjeldsen-Kragh J, Forre O. A pilot study of the effect of an elemental diet in the management of rheumatoid arthritis. Clin Exp Rheumatol. 1994;12(3):275-279. No prevalence or incidence reported. [pmid: 8070160].
Healy D A, Neumyer M M, Atnip R G, et al. Evaluation of celiac and mesenteric vascular disease with duplex ultrasonography. Journal of Ultrasound in Medicine - Official Journal of the American Institute of Ultrasound in Medicine. 1992;11(9):481-485. No prevalence or incidence reported. [pmid: 1491433].
Heederik D, Houba R. An exploratory quantitative risk assessment for high molecular weight sensitizers: Wheat flour. Ann Occup Hyg. 2001;45(3):175-185. No prevalence or incidence reported. [pmid: 11295140].
Heederik D, Thorne P S, Doekes G. Health-based occupational exposure limits for high molecular weight sensitizers: How long is the road we must travel?. Ann Occup Hyg. 2002;46(5):439-446. No prevalence or incidence reported. [pmid: 12176758].
Heikkinen M, Janatuinen E, Mayo K, et al. Usefulness of anti-Helicobacter pylori and anti-CagA antibodies in the selection of patients for gastroscopy. Am J Gastroenterol. 1997;92(12):2225-2229. No prevalence or incidence reported. [pmid: 9399758].
Heikkinen M, Pikkarainen P, Takala J, et al. Etiology of dyspepsia: four hundred unselected consecutive patients in general practice. Scand J Gastroenterol. 1995;30(6):519-523. No prevalence or incidence reported. [pmid: 7569757].
Heinersdorff N, Taylor T G. Concentration of zinc in the hair of schoolchildren. Arch Dis Child. 1979;54(12):958-960. No prevalence or incidence reported. [pmid: 533300].
Hendrikse W H, Reilly J J, Weaver L T. Malnutrition in a children's hospital. Clin Nutr. 1997;16(1):13-18. No prevalence or incidence reported.
Heneghan M A, Stevens F M, Cryan E M, et al. Celiac sprue and immunodeficiency states: a 25-year review. J Clin Gastroenterol. 1997;25(2):421-425. No prevalence or incidence reported. [pmid: 9412941].
Herlinger H, Maglinte D D. Jejunal fold separation in adult celiac disease: relevance of enteroclysis. Radiology. 1986;158(3):605-611. No prevalence or incidence reported. [pmid: 3945730].
Hernandez J L, Michalski J P, McCombs C C, et al. Evidence for a dominant gene mechanism underlying coeliac disease in the west of Ireland. Genet Epidemiol. 1991;8(1):13-27. No prevalence or incidence reported. [pmid: 2060769].
Hernandez M A, Colina G, Ortigosa L. Epilepsy, cerebral calcifications and clinical or subclinical coeliac disease. Course and follow up with gluten-free diet. Seizure - the Journal of the British Epilepsy Association. 1998;7(1):49-54. No prevalence or incidence reported. [pmid: 9548226].
Hernell O, Ivarsson A, Persson L A. Coeliac disease: Effect of early feeding on the incidence of the disease. Early Hum Dev. 2001;65(Suppl 2):S153-S160. No prevalence or incidence reported. [pmid: 11755046].
Herrera M, Chertkoff L, Palavecino E, et al. Restriction fragment length polymorphism in HLA class II genes of Latin-American Caucasian celiac disease patients. Hum Immunol. 1989;26(4):272-280. No prevalence or incidence reported. [pmid: 2573590].
Herrera M, Theiler G, Augustovski F, et al. Molecular characterization of HLA class II genes in celiac disease patients of Latin American Caucasian origin. Tissue Antigens. 1994;43(2):83-87. No prevalence or incidence reported. [pmid: 8016846].
Hertervig E, Wieslander J, Johansson C, et al. Anti-neutrophil cytoplasmic antibodies in chronic inflammatory bowel disease. Prevalence and diagnostic role. Scand J Gastroenterol. 1995;30(7):693-698. No prevalence or incidence reported. [pmid: 7481534].
Hervonen K, Hakanen M, Kaukinen K, et al. First-degree relatives are frequently affected in coeliac disease and dermatitis herpetiformis. Scand J Gastroenterol. 2002;37(1):51-55. Not a relevant screening test. [pmid: 11843035].
Hetzel P A S, LaBrooy J T, Bellon M. The sup 5sup 1Cr EDTA absorption test in coeliac patients treated with a gluten free diet. Ircs Med Sci. 1986;14(12):1183-1184. No prevalence or incidence reported.
Hetzel P A, Bennett G D, Sheldon A B, et al. Genetic markers in Australian Caucasian subjects with coeliac disease. Tissue Antigens. 1987;30(1):18-22. No prevalence or incidence reported. [pmid: 3118502].
Hilhorst M I, Brink M, Wauters E A K, et al. Down syndrome and coeliac disease: Five new cases with a review of the literature. Eur J Pediatr. 1993;152(11):884-887. No prevalence or incidence reported. [pmid: 8276016].
Hill A V S. Immunogenetics and genomics. Lancet. 2001;357(9273):2037-2041. No prevalence or incidence reported. [pmid: 11747915].
Hill D J, Hosking C S, Zhie C Y, et al. The frequency of food allergy in Australia and Asia. Environ Toxicol Pharmacol. 1997;4(12):101-110. No prevalence or incidence reported.
Hill D J, Hudson I L, Sheffield L J, et al. A low allergen diet is a significant intervention in infantile colic: results of a community-based study. J Allergy Clin Immunol. 1995;96(6 Pt 1):886-892. No prevalence or incidence reported. [pmid: 8543745].
Hill I D. Celiac disease - A never-ending story?. Eur J Pediatr. 2003;143(3):289-291. No prevalence or incidence reported.
Hill L E. Hypogammaglobulinaemia in the United Kingdom. 3. Clinical features of hypogammaglobulinaemia. Special Report Series,.Medical Research Council (Great Britain) 1971;3109–34. No prevalence or incidence reported
Hillemeier C, Gryboski J. Diabetes and the gastrointestinal tract in the pediatric patient. Yale J Biol Med. 1983;56(3):195-201. No prevalence or incidence reported. [pmid: 6659562].
Hitman G A, Niven M J, Festenstein H, et al. HLA class II alpha chain gene polymorphisms in patients with insulin-dependent diabetes mellitus, dermatitis herpetiformis, and celiac disease. Eur J Clin Invest. 1987;79(2):609-615. No prevalence or incidence reported.
Hjelt K, Krasilnikoff P A. The impact of gluten on haematological status, dietary intakes of haemopoietic nutrients and vitamin B12 and folic acid absorption in children with coeliac disease. Acta Paediatr Scand. 1990;79(10):911-919. No prevalence or incidence reported. [pmid: 2267921].
Hobbs J R. Immunoflobulins and malabsorption. Proc R Soc Med. 1969;62(10):982-985. No prevalence or incidence reported. [pmid: 4186666]. [pmcid: 1810795].
Hodges S, Lobo-Yeo A, Donaldson P, et al. Autoimmune chronic active hepatitis in a family. Gut. 1991;32(3):299-302. No prevalence or incidence reported. [pmid: 2013424]. [pmcid: 1378838].
Hoey John. Irritable bowel syndrome: could it be celiac disease?. Cmaj - Canadian Medical Association Journal = Journal De L'association Medicale Canadienne. 2002;166(4):479-480. No prevalence or incidence reported.
Hoffbrand A V. Anaemia in adult coeliac disease. Clin Gastroenterol. 1974;3(1):71-89. No prevalence or incidence reported. [pmid: 4599262].
Hoffenberg E J, Bao F, Eisenbarth G S, et al. Transglutaminase antibodies in children with a genetic risk for celiac disease. Eur J Pediatr. 2000;137(3):356-360. Not a relevant screening group.
Hoffmann Jorg C, Zeitz Martin. Small bowel disease in the elderly: diarrhoea and malabsorption. Best Practice & Research. Clinical Gastroenterology. 2002;16(1):17-36. No prevalence or incidence reported. [pmid: 11977926].
Hoffmann M, Vogelsang H, Kletter K, et al. 18F-fluoro-deoxy-glucose positron emission tomography (18F-FDG-PET) for assessment of enteropathy-type T cell lymphoma. Gut. 2003;52(3):347-351. No prevalence or incidence reported. [pmid: 12584214]. [pmcid: 1773540].
Hogberg L, Nordwall M, Stenhammar L. One thousand small-bowel biopsies in children. A single-port versus a double-port capsule. Scand J Gastroenterol. 2001;36(11):1230-1232. No prevalence or incidence reported. [pmid: 11686227].
Hoggan R. Considering wheat, rye, and barley proteins as aids to carcinogens. Med Hypotheses. 1997;49(3):285-288. No prevalence or incidence reported. [pmid: 9293475].
Holden Wendy, Orchard Tim, Wordsworth Paul. Enteropathic arthritis. Rheum Dis Clin North Am 2003;29(3):513–30, Viii. No prevalence or incidence reported
Holm K, Maki M, Savilahti E, et al. Intraepithelial gamma delta T-cell-receptor lymphocytes and genetic susceptibility to coeliac disease. Lancet. 1992;339(8808):1500-1503. No prevalence or incidence reported. [pmid: 1351185].
Holmes G K T. Coeliac disease and malignancy. Ann Nestle. 1993;51(2):66-74. No prevalence or incidence reported.
Holmes G K T. Coeliac disease and malignancy. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(3):229-237. No prevalence or incidence reported. [pmid: 11990397].
Holmes G K T. Screening for coeliac disease in type 1 diabetes. Arch Dis Child. 2002;87(6):495-498. No prevalence or incidence reported. [pmid: 12456547].
Holmes G K, Prior P, Lane M R, et al. Malignancy in coeliac disease--effect of a gluten free diet. Gut. 1989;30(3):333-338. No prevalence or incidence reported. [pmid: 2707633]. [pmcid: 1378455].
Holmes G K, Stokes P L, Sorahan T M, et al. Coeliac disease, gluten-free diet, and malignancy. Gut. 1976;17(8):612-619. No prevalence or incidence reported. [pmid: 789184]. [pmcid: 1411326].
Holmes G K. Celiac disease and malignancy. J Pediatr Gastroenterol Nutr. 1997;24(5):S20-S23. No prevalence or incidence reported. [pmid: 9161971].
Holmes G K. Coeliac disease and Type 1 diabetes mellitus - the case for screening. Diabetic Medicine - a Journal of the British Diabetic Association. 2001;18(3):169-177. No prevalence or incidence reported. [pmid: 11318836].
Holmes G K. Non-malignant complications of coeliac disease. Acta Paediatr. 1996;412(Suppl):68-75. No prevalence or incidence reported.
Holmgren Peterson K, Falth-Magnusson K, Magnusson K-E, et al. Children with celiac disease express inducible nitric oxide synthase in the small intestine during gluten challenge. Scand J Gastroenterol. 1998;33(9):939-943. No prevalence or incidence reported. [pmid: 9759949].
Holopainen P, Arvas M, Sistonen P, et al. CD28/CTLA4 gene region on chromosome 2q33 confers genetic susceptibility to celiac disease. A linkage and family-based association study. Tissue Antigens. 1999;53(5):470-475. No prevalence or incidence reported. [pmid: 10372542].
Holopainen P, Mustalahti K, Uimari P, et al. Candidate gene regions and genetic heterogeneity in gluten sensitivity. Gut. 2001;48(5):696-701. No prevalence or incidence reported. [pmid: 11302971]. [pmcid: 1728294].
Holt P R. The small intestine. Clin Gastroenterol. 1985;14(4):689-723. No prevalence or incidence reported. [pmid: 3936649].
Holt Peter R. Gastrointestinal diseases in the elderly. Curr Opin Clin Nutr Metab Care. 2003;6(1):41-48. No prevalence or incidence reported. [pmid: 12496680].
Holtmeier J, Leuschner U. Medical treatment of primary biliary cirrhosis and primary sclerosing cholangitis. Digestion. 2001;64(3):137-150. No prevalence or incidence reported. [pmid: 11786661].
Hooft C, Devos E, Van Damme J. Coeliac disease in a diabetic child. Lancet. 1969;2(7612):161. No prevalence or incidence reported. [pmid: 4183272].
Hooft C, Roels H, Devos E. Diabetes and coeliac disease. Lancet. 1969;2(7631):1192. No prevalence or incidence reported. [pmid: 4187221].
Hornell A, Hofvander Y, Kylberg E. Introduction of solids and formula to breastfed infants: A longitudinal prospective study in Uppsala, Sweden. Acta Paediatr Int J Paediatr. 2001;90(5):477-482. No prevalence or incidence reported.
Horvath K, Hill I D. Anti-tissue transglutaminase antibody as the first line screening for celiac disease: Good-bye antigliadin tests?. Am J Gastroenterol. 2002;97(11):2702-2704. No prevalence or incidence reported. [pmid: 12425536].
Horvath K, Horn G. Tardyferon therapy in hyposiderosis of infancy and childhood. Ther Hung. 1992;40(1):40-43. No prevalence or incidence reported. [pmid: 1585284].
Horvath K, Mehta D I. Celiac disease--a worldwide problem. Indian J Pediatr. 2000;67(10):757-763. No prevalence or incidence reported. [pmid: 11105427].
Houba R, Heederik D, Doekes G. Wheat sensitization and work-related symptoms in the baking industry are preventable: An epidemiologic study. Am J Respir Crit Care Med. 1998;158(5 I):1499-1503. No prevalence or incidence reported. [pmid: 9817699].
Houlston R S, Ford D. Genetics of coeliac disease. Qjm - Monthly Journal of the Association of Physicians. 1996;89(10):737-743. No prevalence or incidence reported. [pmid: 8944229].
Houlston R S, Tomlinson I P, Ford D, et al. Linkage analysis of candidate regions for coeliac disease genes. Hum Mol Genet. 1997;6(8):1335-1339. No prevalence or incidence reported. [pmid: 9259281].
Hourihane J O, Strobel S. Clinical features of food allergy. Comments Toxicol. 2002;8(3):307-319. No prevalence or incidence reported.
Hourihane J O. Prevalence and severity of food allergy--need for control. Allergy. 1998;53(46 Suppl):84-88. No prevalence or incidence reported. [pmid: 9826008].
Hovdenak N. Prevalence and clinical picture of adult gluten-induced enteropathy in a Norwegian population. Scand J Gastroenterol. 1980;15(4):401-404. Unable to obtain full article. [pmid: 7433901].
Hovell C J, Collett J A, Vautier G, et al. High prevalence of coeliac disease in a population-based study from Western Australia: a case for screening?. Med J Aust. 2001;175(5):247-250. Not a relevant screening geography. [pmid: 11587254].
Howard F M, Carter C O, Candy D C, et al. A family study of protracted diarrhoea in infancy. J Med Genet. 1981;18(2):81-86. No prevalence or incidence reported. [pmid: 7241538].
Howdle P D, Jalal P K, Holmes G K T, et al. Primary small-bowel malignancy in the UK and its association with coeliac disease. Qjm - Monthly Journal of the Association of Physicians. 2003;96(5):345-353. No prevalence or incidence reported. [pmid: 12702783].
Howell W, Martin Calder, Philip C, et al. Gene polymorphisms, inflammatory diseases and cancer. Proc Nutr Soc. 2002;61(4):447-456. No prevalence or incidence reported. [pmid: 12691174].
Hozyasz K K. Sex ratio variation in offspring of celiac women - Preliminary report. Pediatr Wspolczesna. 2002;4(3):253-255. No prevalence or incidence reported.
Hummel M, Bonifacio E, Stern M, et al. Development of celiac disease-associated antibodies in offspring of parents with type I diabetes. Diabetologia. 2000;43(8):1005-1011. No prevalence or incidence reported. [pmid: 10990078].
Hummel M, Ziegler A G, Bonifacio E. Type 1 diabetes mellitus, celiac disease and their association--lessons from antibodies. Journal of Pediatric Endocrinology & Metabolism - Jpem. 2001;14(Suppl 1):607-610. No prevalence or incidence reported. [pmid: 11393551].
Hurley T H, Sullivan J R, Hurley J V. Reaction to Kveim test material in sarcoidosis and other diseases. Lancet. 1975;1(7905):494-496. No prevalence or incidence reported. [pmid: 46962].
Hussain G, Ali S, Iqbal M M, et al. Study of coeliac disease in children. J Coll Phys Surg Pak. 1999;9(2):81-84. Not a relevant screening geography.
Hyams J S, Treem W R, Justinich C J, et al. Characterization of symptoms in children with recurrent abdominal pain: resemblance to irritable bowel syndrome. J Pediatr Gastroenterol Nutr. 1995;20(2):209-214. No prevalence or incidence reported. [pmid: 8583293].
Hyams J S. Celiac disease: New thoughts an an old problem. Curr Opin Pediatr. 1997;9(5):487-489. No prevalence or incidence reported. [pmid: 9360827].
Hyer W, Cotterill A M, Savage M O. Common causes of short stature detectable by a height surveillance programme. J Med Screen. 1995;2(3):150-153. No prevalence or incidence reported. [pmid: 8536185].
Hylander E, Jarnum S, Kempel K, et al. The absorption of oxalate, calcium, and fat after jejunoileal bypass. A prospective study. Scand J Gastroenterol. 1980;15(3):343-348. No prevalence or incidence reported. [pmid: 7433894].
Iacono G, Carroccio A, Montalto G, et al. Steatocrit test: normal range and physiological variations in preterm and low-birth-weight full-term newborns. Acta Paediatr. 1992;81(11):933-934. No prevalence or incidence reported. [pmid: 1467618].
Ide A, Eisenbarth G S. Genetic susceptibility in type 1 diabetes and its associated autoimmune disorders. Rev Endocr Metab Disord. 2003;4(3):243-253. No prevalence or incidence reported. [pmid: 14501175].
Iglesias S, Chapon F, Baron J C. Familial occipital calcifications, hemorrhagic strokes, leukoencephalopathy, dementia, and external carotid dysplasia. Neurology. 2000;55(11):1661-1667. No prevalence or incidence reported. [pmid: 11113220].
Iltanen S, Collin P, Korpela M, et al. Celiac disease and markers of celiac disease latency in patients with primary Sjogren's syndrome. Am J Gastroenterol. 1999;94(4):1042-1046. Not a relevant screening group. [pmid: 10201480].
Ilyas M, Niedobitek G, Agathanggelou A, et al. Non-Hodgkin's lymphoma, coeliac disease, and Epstein-Barr virus: a study of 13 cases of enteropathy-associated T- and B-cell lymphoma. Am J Pathol. 1995;177(2):115-122. No prevalence or incidence reported.
Imai T, Akasawa A, Iikura Y. Nationwide food allergy survey. Int Arch Allergy Immunol. 2001;124(13):312-314. No prevalence or incidence reported.
Iovino P, Ciacci C, Sabbatini F, et al. Esophageal impairment in adult celiac disease with steatorrhea. Am J Gastroenterol. 1998;93(8):1243-1249. No prevalence or incidence reported. [pmid: 9707045].
ipetic S, Vlajinac H, Kocev N, et al. Family history and risk of type 1 diabetes mellitus. Acta Diabetol Lat. 2002;39(3):111-115. No prevalence or incidence reported.
Isaacson P G. Gastrointestinal lymphomas of T- and B-cell types. Mod Pathol. 1999;12(2):151-158. No prevalence or incidence reported. [pmid: 10071340].
Isaksson B, Lindholm B, Sjogren B. A critical evaluation of the calcium balance technic. II. Dermal calcium losses. Metabolism- Clinical and Experimental. 1967;16(4):303-313. No prevalence or incidence reported. [pmid: 6024156].
Isbell R G, Carlson H C, Hoffman H N. Roentgenologic-pathologic correlation in malabsorption syndromes. Am J Roentgenol Radium Ther Nucl Med. 1969;107(1):158-169. No prevalence or incidence reported. [pmid: 5811553].
Iughetti L, Bulgarelli S, Forese S, et al. Endocrine aspects of coeliac disease. Journal of Pediatric Endocrinology & Metabolism - Jpem. 2003;16(6):805-818. No prevalence or incidence reported. [pmid: 12948292].
Ivarsson A, Hernell O, Nystrom L, et al. Children born in the summer have increased risk for coeliac disease. J Epidemiol Community Health. 2003;57(1):36-39. No prevalence or incidence reported. [pmid: 12490646].
Ivarsson A, Hernell O, Stenlund H, et al. Breast-feeding protects against celiac disease. Am J Clin Nutr. 2002;75(5):914-921. No prevalence or incidence reported. [pmid: 11976167].
Ivarsson A, Persson L A, Hernell O. Does breast-feeding affect the risk for coeliac disease?. Adv Exp Med Biol 2000;478139–149. No prevalence or incidence reported
Ivarsson A. On the multifactorial aetiology of coeliac disease. Scand J Nutr Naringsforsk. 2001;45(4):184-185. No prevalence or incidence reported.
Ivarsson S A, Carlsson A, Bredberg A, et al. Prevalence of coeliac disease in Turner syndrome. Acta Paediatr. 1999;88(9):933-936. Not a relevant screening group. [pmid: 10519331].
Iwanczak F, Mozrzymas R, Heimrath Z, et al. Clinical evaluation of food allergy and food intolerance dietary treatment in children. Rocz Akad Med Bialymst. 1995;40(3):588-594. No prevalence or incidence reported. [pmid: 8775311].
Jabbar A A R. HLA and disease associations in Iraq. Dis Markers. 1993;11(4):161-170. No prevalence or incidence reported. [pmid: 8112020].
Jackson F. The coevolutionary relationship of humans and domesticated plants. Am J Phys Anthropol 1996;-(Suppl 23):161–176. No prevalence or incidence reported
James M W, Scott B B. Coeliac disease: the cause of the various associated disorders?. Eur J Gastroenterol Hepatol. 2001;13(9):1119-1121. No prevalence or incidence reported. [pmid: 11564967].
James M W, Scott B B. Evidence-based clinical medicine: Application of a diagnostic test using the example of coeliac disease. Cme J Gastroenterol Hepatol Nutr. 2001;4(1):28-31. No prevalence or incidence reported.
James O F W. NASH/NAFLD management. Acta Gastro-Enterol Belg. 2002;65(4):200-203. No prevalence or incidence reported.
Jameson S. Zinc status in pregnancy: the effect of zinc therapy on perinatal mortality, prematurity, and placental ablation. Ann N Y Acad Sci 1993;678178–192. No prevalence or incidence reported
Janatkova I, Malic caron, Fu caron, et al. Diagnostic asset of assessment of autoantibodies in gluten-sensitive enteropathy. Epidemiol Mikrobiol Imunol. 2002;51(3):125-130. No prevalence or incidence reported. [pmid: 12184191].
Janatuinen E K, Kemppainen T A, Julkunen R J K, et al. No harm from five year ingestion of oats in coeliac disease. Gut. 2002;50(3):332-335. No prevalence or incidence reported. [pmid: 11839710]. [pmcid: 1773136].
Jansson U, Johansson C. Down syndrome and celiac disease. J Pediatr Gastroenterol Nutr. 1995;21(4):443-445. No prevalence or incidence reported. [pmid: 8583297].
Jarvinen K-M, Turpeinen M, Suomalainen H. Concurrent cereal allergy in children with cow's milk allergy manifested with atopic dermatitis. Clin Exp Allergy. 2003;33(8):1060-1066. No prevalence or incidence reported. [pmid: 12911779].
Jawhari A, Talbot I C. Microscopic, lymphocytic and collagenous colitis. Histopathology. 1996;29(2):101-110. No prevalence or incidence reported. [pmid: 8872143].
Jaworski Z F. Pathophysiology, diagnosis and treatment of osteomalacia. Orthop Clin North Am. 1972;3(3):623-652. No prevalence or incidence reported. [pmid: 4565584].
Jeffrey P, Griffin P, Gibson M, et al. Small bakeries - A cross-sectional study of respiratory symptoms, sensitization and dust exposure. Occup Med. 1999;49(4):237-241. No prevalence or incidence reported.
Jenkins D J A, Taylor R H, Wolever T M S. The diabetic diet, dietary carbohydrate and differences in digestibility. Diabetologia. 1982;23(6):477-484. No prevalence or incidence reported. [pmid: 6295862].
Jenkins D, Goodall A, Scott B B. T-lymphocyte populations in normal and coeliac small intestinal mucosa defined by monoclonal antibodies. Gut. 1986;27(11):1330-1337. No prevalence or incidence reported. [pmid: 3491776]. [pmcid: 1434057].
Jenkins D, Goodall A, Scott B. T-cell and plasma cell populations in coeliac small intestinal mucosa in relation to dermatitis herpetiformis. Gut. 1989;30(7):955-958. No prevalence or incidence reported. [pmid: 2788114]. [pmcid: 1434300].
Jennings J S R, Howdle P D. Celiac disease. Curr Opin Gastroenterol. 2001;17(2):118-126. No prevalence or incidence reported. [pmid: 11224666].
Jevon G P, Dimmick J E, Dohil R, et al. Spectrum of gastritis in celiac disease in childhood. Pediatric and Developmental Pathology - the Official Journal of the Society for Pediatric Pathology and the Paediatric Pathology Society. 1999;2(3):221-226. No prevalence or incidence reported. [pmid: 10191345].
Jewell D P. Celiac disease. Can J Gastroenterol. 2000;14(8):665-666. No prevalence or incidence reported. [pmid: 11185528].
Jiskra J, Limanova Z, Vanic caron, et al. IgA and IgG antigliadin, IgA anti-tissue transglutaminase and antiendomysial antibodies in patients with autoimmune thyroid diseases and their relationship to thyroidal replacement therapy. Physiol Res. 2003;52(1):79-88. No prevalence or incidence reported. [pmid: 12625811].
Johanns W, Jakobeit C, Greiner L, et al. Ultrasound-guided extracorporeal shock wave lithotripsy of pancreatic ductal stones: six years' experience. Can J Gastroenterol. 1996;10(7):471-475. No prevalence or incidence reported. [pmid: 9113891].
Johansen B H, Buus S, Vartdal F, et al. Binding of peptides to HLA-DQ molecules: Peptide binding properties of the disease-associated HLA-DQ(alpha1(*)0501, beta1(*)0201) molecule. Int Immunol. 1994;6(3):453-461. No prevalence or incidence reported. [pmid: 8186196].
Johansen B H, Jensen T, Thorpe C J, et al. Both alpha and beta chain polymorphisms determine the specificity of the disease-associated HLA-DQ2 molecules, with beta chain residues being most influential. Immunogenetics. 1996;45(2):142-150. No prevalence or incidence reported. [pmid: 8952964].
Johansen B H, Vartdal F, Eriksen J A, et al. Identification of a putative motif for binding of peptides to HLA-DQ2. Int Immunol. 1996;8(2):177-182. No prevalence or incidence reported. [pmid: 8671602].
Johnell O, Obrant K J. What is the impact of osteoporosis?. Bailliere's Clin Rheumatol. 1997;11(3):459-477. No prevalence or incidence reported. [pmid: 9367032].
Johnson T N, Tanner M S, Taylor C J, et al. Enterocytic CYP3A4 in a paediatric population: developmental changes and the effect of coeliac disease and cystic fibrosis. Br J Clin Pharmacol. 2001;51(5):451-460. No prevalence or incidence reported. [pmid: 11422003]. [pmcid: 2014473].
Johnston S D, Peter Watson R G, McMillan S A. Soda bread provocation test for subjects with transient serology for coeliac disease 3 years after a population screening survey. Eur J Gastroenterol Hepatol. 2000;12(9):1013-1015. No prevalence or incidence reported. [pmid: 11007138].
Johnston S D, Ritchie C, Robinson J. Application of red cell distribution width to screening for coeliac disease in insulin-dependent diabetes mellitus. Ir J Med Sci. 1999;168(3):167-170. No prevalence or incidence reported. [pmid: 10540781].
Johnston S D, Watson R G P, McMillan S A, et al. Prevalence of coeliac disease in Northern Ireland. Lancet. 1997;350(9088):1370. Not a relevant screening test. [pmid: 9365462].
Johnston S D, Watson R G P. Small bowel lymphoma in unrecognized coeliac disease: A cause for concern?. Eur J Gastroenterol Hepatol. 2000;12(6):645-648. No prevalence or incidence reported. [pmid: 10912485].
Johnston S D, Watson R G, McMillan S A, et al. Preliminary results from follow-up of a large-scale population survey of antibodies to gliadin, reticulin and endomysium. Acta Paediatr. 1996;412(Suppl):61-64. Not a relevant screening test.
Johnston S D, Watson R G, McMillan S A, et al. Serological markers for coeliac disease: changes with time and relationship to enteropathy. Eur J Gastroenterol Hepatol. 1998;10(3):259-264. No prevalence or incidence reported. [pmid: 9585032].
Johnston S D, Watson R G, Middleton D, et al. Genetic, morphometric and immunohistochemical markers of latent coeliac disease. Eur J Gastroenterol Hepatol. 1999;11(11):1283-1288. No prevalence or incidence reported. [pmid: 10563541].
Johnston Simon D, McMillan Stanley A, Collins John S, et al. A comparison of antibodies to tissue transglutaminase with conventional serological tests in the diagnosis of coeliac disease. Eur J Gastroenterol Hepatol. 2003;15(9):1001-1004. No prevalence or incidence reported. [pmid: 12923373].
Jokinen J, Peters U, Maki M, et al. Celiac sprue in patients with chronic oral mucosal symptoms. J Clin Gastroenterol. 1998;26(1):23-26. No prevalence or incidence reported. [pmid: 9492858].
Jones S M, Magnolfi C F, Cooke S K, et al. Immunologic cross-reactivity among cereal grains and grasses in children with food hypersensitivity. J Allergy Clin Immunol. 1995;96(3):341-351. No prevalence or incidence reported. [pmid: 7560636].
Kaczmarski M, Kurzatkowska B. The contribution of some constitutional factors to the development of cow's milk and gluten intolerance in children. Rocz Akad Med Bialymst 1989;33-34167-76. No prevalence or incidence reported
Kaczmarski M, Kurzatkowska B. The contribution of some environmental factors to the development of cow's milk and gluten intolerance in children. Rocz Akad Med Bialymst 1989;33-34151-165. No prevalence or incidence reported
Kaerlev L, Teglbjaerg P S, Sabroe S, et al. Medical risk factors for small-bowel adenocarcinoma with focus on Crohn disease: a European population-based case-control study. Scand J Gastroenterol. 2001;36(6):641-646. No prevalence or incidence reported. [pmid: 11424324].
Kagnoff M F, Weiss J B, Brown R J. Immunoglobulin allotype markers in gluten-sensitive enteropathy. Lancet. 1983;1(8331):952-953. No prevalence or incidence reported. [pmid: 6132268].
Kainulainen H, Rantala I, Collin P, et al. Blisters in the small intestinal mucosa of coeliac patients contain T cells positive for cyclooxygenase 2. Gut. 2002;50(1):84-89. No prevalence or incidence reported. [pmid: 11772972]. [pmcid: 1773065].
Kalapesi Z, Rees J P R. Coeliac disease in schoolchildren. Ir Med J. 1978;71(6):188-191. No prevalence or incidence reported. [pmid: 649327].
Kalayci A G, Kansu A, Girgin N, et al. Bone mineral density and importance of a gluten-free diet in patients with celiac disease in childhood. Pediatrics. 2001;108(5):E89. No prevalence or incidence reported. [pmid: 11694673].
Kallikorm R, Uibo O, Uibo R. Coeliac disease in spondyloarthropathy: usefulness of serological screening. Clin Rheumatol. 2000;19(2):118-122. No prevalence or incidence reported. [pmid: 10791622].
Kalra K K, Jain N, Mittal S K. Management of celiac disease. Indian J Pediatr. 1999;66(1 Suppl):S32-S36. No prevalence or incidence reported. [pmid: 11132466].
Kansu A, Kalayci A G, Altuntas B, et al. Autoimmune hepatitis in children: A report of ten cases. Turk J Med Sci. 2000;30(1):55-61. No prevalence or incidence reported.
Kanungo A, Samal K C, Sanjeevi C B. Molecular mechanisms involved in the etiopathogenesis of malnutrition-modulated diabetes mellitus. Ann N Y Acad Sci 2002;958138–143. No prevalence or incidence reported
Kanungo A, Shtauvere-Brameus A, Samal K C et al. Autoantibodies to tissue transglutaminase in patients from eastern India with malnutrition-modulated diabetes mellitus, insulin-dependent diabetes mellitus, and non-insulin-dependent diabetes mellitus. Ann N Y Acad Sci 2002;958232–234. Not a relevant screening geography
Karagiozoglou-Lampoudi T, Nousia-Arvanitaki S, Augoustidou-Savopoulou P, et al. Insulin secretion decline unrelated to jejunal morphology or exocrine pancreatic function in children with celiac disease. Journal of Pediatric Endocrinology & Metabolism - Jpem. 1996;9(6):585-591. No prevalence or incidence reported. [pmid: 9004173].
Karczewska K, Lukasik M, Kasner J, et al. Familial occurrence of celiac disease and isolated immunoglobulin a deficiency. Med Sci Monit. 1998;4(5):836-839. No prevalence or incidence reported.
Karell K, Holopainen P, Mustalahti K, et al. Not all HLA DR3 DQ2 haplotypes confer equal susceptibility to coeliac disease: transmission analysis in families. Scand J Gastroenterol. 2002;37(1):56-61. No prevalence or incidence reported. [pmid: 11843036].
Karell K, Korponay-Szabo I, Szalai Zs, et al. Genetic dissection between coeliac disease and dermatitis herpetiformis in sib pairs. Ann Hum Genet. 2002;66(Pt 56):387-392. No prevalence or incidence reported. [pmid: 12485471].
Kariv R, Arber N. Malignant tumors of the small intestine - New insights into a rare disease. Isr Med Assoc J. 2003;5(3):188-192. No prevalence or incidence reported. [pmid: 12725140].
Kasperlik-Zal(stroke)uska A A, Czarnocka B, Czech W. Autoimmunity as the most frequent cause of idiopathic secondary adrenal insufficiency: Report of 111 cases. Autoimmunity. 2003;36(3):155-159. No prevalence or incidence reported. [pmid: 12911282].
Kastin D A, Buchman A L. Malnutrition and gastrointestinal disease. Curr Opin Gastroenterol. 2002;18(2):221-228. No prevalence or incidence reported. [pmid: 17033291].
Katz A J, Falchuk Z M. Current concepts in gluten sensitive enteropathy (celiac sprue). Pediatr Clin North Am. 1975;22(4):767-785. No prevalence or incidence reported. [pmid: 1105361].
Katz K D. Celiac Disease - Current Clinical Considerations in Treatment and Avoidance of Nutritional Deficiencies. Today's Ther Trends. 2003;21(4):379-389. No prevalence or incidence reported.
Kaukinen K, Collin P, Holm K, et al. Small-bowel mucosal inflammation in reticulin or gliadin antibody-positive patients without villous atrophy. Scand J Gastroenterol. 1998;33(9):944-949. No prevalence or incidence reported. [pmid: 9759950].
Kaukinen K, Collin P, Holm K, et al. Wheat starch-containing gluten-free flour products in the treatment of coeliac disease and dermatitis herpetiformis. A long-term follow-up study. Scand J Gastroenterol. 1999;34(2):163-169. No prevalence or incidence reported. [pmid: 10192194].
Kaukinen K, Maki M, Partanen J, et al. Celiac disease without villous atrophy: revision of criteria called for. Dig Dis Sci. 2001;46(4):879-887. No prevalence or incidence reported. [pmid: 11330428].
Kaukinen Katri, Sulkanen Satu, Maki Markku, et al. IgA-class transglutaminase antibodies in evaluating the efficacy of gluten-free diet in coeliac disease. Eur J Gastroenterol Hepatol. 2002;14(3):311-315. No prevalence or incidence reported. [pmid: 11953698].
Kaur Gurvinder, Sarkar N, Bhatnagar S, et al. Pediatric celiac disease in India is associated with multiple DR3-DQ2 haplotypes. Hum Immunol. 2002;63(8):677-682. No prevalence or incidence reported. [pmid: 12121676].
Kavin H. Adult coeliac disease in South Africa. An analysis of 20 cases emphasizing atypical presentations. South African Medical Journal. Suid-Afrikaanse Tydskrif Vir Geneeskunde. 1981;59(18):628-632. No prevalence or incidence reported. [pmid: 7221782].
Kawasaki E, Eisenbarth G S. High-throughput radioassays for autoantibodies to recombinant autoantigens. Front Biosci. 2000;5:e181-e190. No prevalence or incidence reported. [pmid: 11056082].
Kaye P S. Osteoporosis and fracture as a result of gastrointestinal and hepatic disorders. Pract Gastroenterol. 1999;23(3):15-34. No prevalence or incidence reported.
Keaveny A P, Freaney R, McKenna M J, et al. Bone remodeling indices and secondary hyperparathyroidism in celiac disease. Am J Gastroenterol. 1996;91(6):1226-1231. No prevalence or incidence reported. [pmid: 8651176].
Kedzierska A, Turowski G. HLA class I antigens in families with coeliac disease. Medical Science Monitor - International Medical Journal of Experimental and Clinical Research. 2000;6(5):957-963. No prevalence or incidence reported. [pmid: 11208438].
Kedzierska A, Turowski G. HLA class I haplotypes in families of children with coeliac disease. Medical Science Monitor - International Medical Journal of Experimental and Clinical Research. 2000;6(2):336-341. No prevalence or incidence reported. [pmid: 11208438].
Keeton G R. Malabsorption in the Bantu. South African Medical Journal. Suid-Afrikaanse Tydskrif Vir Geneeskunde. 1972;46(33):1170-1174. No prevalence or incidence reported. [pmid: 5079695].
Kellock T D, Pearson J R, Russell R I, et al. The incidence and clinical significance of faecal hydroxy fatty acids. Gut. 1969;10(12):1055. No prevalence or incidence reported. [pmid: 5366269].
Kelly D A, Phillips A D, Elliott E J, et al. Rise and fall of coeliac disease 1960-85. Arch Dis Child. 1989;64(8):1157-1160. No prevalence or incidence reported. [pmid: 2782929].
Kelly J, O'Farrelly C, Rees J P, et al. Humoral response to alpha gliadin as serological screening test for coeliac disease. Arch Dis Child. 1987;62(5):469-473. No prevalence or incidence reported. [pmid: 3606179].
Kemppainen T A, Kosma V M, Janatuinen E K, et al. Nutritional status of newly diagnosed celiac disease patients before and after the institution of a celiac disease diet--association with the grade of mucosal villous atrophy. Am J Clin Nutr. 1998;67(3):482-487. No prevalence or incidence reported. [pmid: 9497194].
Kemppainen T, Kroger H, Janatuinen E, et al. Bone recovery after a gluten-free diet: a 5-year follow-up study. Bone. 1999;25(3):355-360. No prevalence or incidence reported. [pmid: 10495140].
Kemppainen T, Kroger H, Janatuinen E, et al. Osteoporosis in adult patients with celiac disease. Bone. 1999;24(3):249-255. No prevalence or incidence reported. [pmid: 10495140].
Kemppainen T, Uusitupa M, Janatuinen E, et al. Intakes of nutrients and nutritional status in coeliac patients. Scand J Gastroenterol. 1995;30(6):575-579. No prevalence or incidence reported. [pmid: 7569766].
Kennedy N P, Feighery C. Clinical features of coeliac disease today. Biomed Pharmacother. 2000;54(7):373-380. No prevalence or incidence reported. [pmid: 10989976].
Kepczyk T, Cremins J E, Long B D, et al. A prospective, multidisciplinary evaluation of premenopausal women with iron-deficiency anemia. Am J Gastroenterol. 1999;94(1):109-115. No prevalence or incidence reported. [pmid: 9934740].
Kero J, Gissler M, Hemminki E, et al. Could TH1 and TH2 diseases coexist? Evaluation of asthma incidence in children with coeliac disease, type 1 diabetes, or rheumatoid arthritis: a register study. J Allergy Clin Immunol. 2001;108(5):781-783. No prevalence or incidence reported. [pmid: 11692104].
Kerttula T O, Holm K, Partanen J, et al. Circulating T lymphocyte subsets in coeliac disease (CoD) patients and healthy family members. Clin Exp Immunol. 1998;111(3):536-540. No prevalence or incidence reported. [pmid: 9528895]. [pmcid: 1904878].
Keuning J J, Pena A S, van Leeuwen A, et al. HLA-DW3 associated with coeliac disease. Lancet. 1976;1(7958):506-508. No prevalence or incidence reported. [pmid: 55781].
Khoo J, Shek L, Khor E S H, et al. Pattern of sensitization to common environmental allergens amongst atopic Singapore children in the first 3 years of life. Asian Pac J Allergy Immunol. 2001;19(4):225-229. No prevalence or incidence reported. [pmid: 12009071].
Khoshoo V, Bhan M K, Puri S, et al. Serum anti-gliadin antibody profile in childhood protracted diarrhoea due to coeliac disease and other causes in a developing country. Scand J Gastroenterol. 1989;24(10):1212-1216. No prevalence or incidence reported. [pmid: 2602903].
Khuffash F A, Barakat M H, Shaltout A A, et al. Coeliac disease among children in Kuwait: difficulties in diagnosis and management. Gut. 1987;28(12):1595-1599. No prevalence or incidence reported. [pmid: 3428686]. [pmcid: 1433935].
Khulusi S, Rhodes J. Diagnostic dilemmas in colitis. J R Coll Phys London. 1997;31(6):618-623. No prevalence or incidence reported.
Kieffer M, Barnetson R S, Blackwell J N. Sequential studies of gliadin antibodies in patients with dermatitis herpetiformis. Arch Dermatol Res. 1984;276(2):74-77. No prevalence or incidence reported. [pmid: 6721574].
Kieslich M, Errazuriz G, Posselt H G, et al. Brain white-matter lesions in celiac disease: a prospective study of 75 diet-treated patients. Pediatrics. 2001;108(2):E21. No prevalence or incidence reported. [pmid: 11483831].
Kilmartin C, Lynch S, Abuzakouk M, et al. Avenin fails to induce a Th1 response in coeliac tissue following in vitro culture. Gut. 2003;52(1):47-52. No prevalence or incidence reported. [pmid: 12477758]. [pmcid: 1773501].
Kilpatrick Z M, Katz J. Occult celiac disease as a cause of iron deficiency anemia. Jama - the Journal of the American Medical Association. 1969;208(6):999-1001. No prevalence or incidence reported. [pmid: 5818637].
Kim Soo, Youl Jeitner, Thomas M, et al. Transglutaminases in disease. Neurochem Int. 2002;40(1):85-103. No prevalence or incidence reported. [pmid: 11738475].
Kimber Ian, Dearman Rebecca J. Factors affecting the development of food allergy. Proc Nutr Soc. 2002;61(4):435-439. No prevalence or incidence reported. [pmid: 12691172].
King A L, Ciclitira P J. Celiac disease: strongly heritable, oligogenic, but genetically complex. Mol Genet Metab. 2000;71(12):70-75. No prevalence or incidence reported. [pmid: 11001798].
King A L, Fraser J S, Moodie S J, et al. Coeliac disease: follow-up linkage study provides further support for existence of a susceptibility locus on chromosome 11p11. Ann Hum Genet. 2001;65(Pt 4):377-386. No prevalence or incidence reported. [pmid: 11592927].
King A L, Yiannakou J Y, Brett P M, et al. A genome-wide family-based linkage study of coeliac disease. Ann Hum Genet. 2000;64(Pt 6):479-490. No prevalence or incidence reported. [pmid: 11281212].
Kingham J G, Parker D R. The association between primary biliary cirrhosis and coeliac disease: a study of relative prevalences. Gut. 1998;42(1):120-122. No prevalence or incidence reported. [pmid: 9577357]. [pmcid: 1726939].
Kinston W, Loader P, Miller L. Emotional health of families and their members where a child is obese. J Psychosom Res. 1987;31(5):583-599. No prevalence or incidence reported. [pmid: 3430421].
Kiper N, Gocmen A, Ozcelik U, et al. Long-term clinical course of patients with idiopathic pulmonary hemosiderosis (1979-1994): Prolonged survival with low-dose corticosteroid therapy. Pediatr Pulmonol. 1999;27(3):180-184. No prevalence or incidence reported. [pmid: 10213256].
Kitts D, Yuan Y, Joneja J, et al. Adverse reactions to food constituents: allergy, intolerance, and autoimmunity. Can J Physiol Pharmacol. 1997;75(4):241-254. No prevalence or incidence reported. [pmid: 9196849].
Klasen E C, Polanco I, Biemond I, et al. alpha 1-Antitrypsin and coeliac disease in spain. Gut. 1980;21(11):948-950. No prevalence or incidence reported. [pmid: 6969683]. [pmcid: 1419289].
Klipstein F A, Beauchamp I, Corcino J J, et al. Nutritional status and intestinal function among rural populations of the West Indies. II. Barrio Nuevo, Puerto Rico. Gastroenterology. 1972;63(5):758-767. No prevalence or incidence reported. [pmid: 5079486].
Knivsberg A M. Urine patterns, peptide levels and IgA/IgG antibodies to food proteins in children with dyslexia. Pediatr Rehabil. 1997;1(1):25-33. No prevalence or incidence reported. [pmid: 9689235].
Knudtzon J, Fluge G, Aksnes L. Routine measurements of gluten antibodies in children of short stature. J Pediatr Gastroenterol Nutr. 1991;12(2):190-194. No prevalence or incidence reported. [pmid: 2051271].
Kocak N, Varzikoglu M, Yuce A, et al. Celiac disease in childhood: Analysis of 41 cases. Turk J Gastroenterol. 1997;8(2):201-205. No prevalence or incidence reported.
Koch M B, Go V L, DiMagno E P. Can plasma human pancreatic polypeptide be used to detect diseases of the exocrine pancreas?. Mayo Clin Proc. 1985;60(4):259-265. No prevalence or incidence reported. [pmid: 2984484].
Kocna Petr, Vanickova Zdislava, Perusicova Jindriska, et al. Tissue transglutaminase-serology markers for coeliac disease. Clinical Chemistry and Laboratory Medicine - Cclm / Fescc. 2002;40(5):485-492. No prevalence or incidence reported. [pmid: 12113293].
Koivisto V A, Kuitunen P, Tiilikainen A, et al. HLA antigens in patients with juvenile diabetes mellitus, coeliac disease and both of the diseases. Diabete Metab. 1977;3(1):49-53. No prevalence or incidence reported. [pmid: 870355].
Koivisto V A, Kuitunen P, Tilikainen A, et al. HLA antigens, especially B8 and BW15, in patients with juvenile diabetes mellitus, coeliac disease, and both of these diseases [proceedings]. Diabete Metab. 1976;2(3):161. No prevalence or incidence reported. [pmid: 1010138].
Kokkonen J, Holm K, Karttunen T J, et al. Children with untreated food allergy express a relative increment in the density of duodenal gammadeltaSUP+ T cells. Scand J Gastroenterol. 2000;35(11):1137-1142. No prevalence or incidence reported. [pmid: 11145283].
Kokkonen J, Simila S, Vuolukka P. The incidence of coeliac disease and pyloric stenosis in children in Northern Finland. Ann Clin Res. 1982;14(3):123-128. Serology screen <1990. [pmid: 7137881].
Kokkonen J. Lymphonodular hyperplasia on the duodenal bulb indicates food allergy in children. Endoscopy. 1999;31(6):464-467. No prevalence or incidence reported. [pmid: 10494687].
Kolacek S, Petkovic I, Booth I W. Chromosome aberrations in coeliac and non-coeliac enteropathies. Arch Dis Child. 1998;78(5):466-468. No prevalence or incidence reported. [pmid: 9659096].
Kolek A, Vospe caron, Her caron, et al. Occurrence of coeliac disease in children with Down Syndrome in north Moravia, Czech Republic. Eur J Pediatr. 2003;162(3):207-208. No prevalence or incidence reported. [pmid: 12655432].
Koletzko B. Complementary foods and the development of food allergy. Pediatrics. 2000;106(5 II):1285-1286. No prevalence or incidence reported. [pmid: 11061840].
Koletzko S, Burgin-Wolff A, Koletzko B, et al. Prevalence of coeliac disease in diabetic children and adolescents. A multicentre study. Eur J Pediatr. 1988;148(2):113-117. Not a relevant screening geography. [pmid: 3069470].
Kolho K L, Tiitinen A, Tulppala M, et al. Screening for coeliac disease in women with a history of recurrent miscarriage or infertility. Br J Obstet Gynaecol. 1999;106(2):171-173. No prevalence or incidence reported. [pmid: 10426684].
Kolho K-L, Jusufovic J, Miettinen A, et al. Parietal cell antibodies and Helicobacter pylori in children. J Pediatr Gastroenterol Nutr. 2000;30(3):265-268. No prevalence or incidence reported. [pmid: 10749409].
Koning F. Celiac disease and malignancy: an immunological basis?. J Pediatr Gastroenterol Nutr. 1997;24(5):S18-S19. No prevalence or incidence reported. [pmid: 9161970].
Kontakou M, Przemioslo R T, Sturgess R P, et al. Expression of tumour necrosis factor-alpha, interleukin-6, and interleukin-2 mRNA in the jejunum of patients with coeliac disease. Scand J Gastroenterol. 1995;30(5):456-463. No prevalence or incidence reported. [pmid: 7638572].
Kontiainen S, Schlenzka A, Koskimies S, et al. Autoantibodies and autoimmune diseases in young diabetics. Diabetes Res. 1990;13(4):151-156. Serology screen <1990. [pmid: 2134205].
Konzen K M, Perrault J, Moir C, et al. Long-term follow-up of young patients with chronic hereditary or idiopathic pancreatitis. Mayo Clin Proc. 1993;68(5):449-453. No prevalence or incidence reported. [pmid: 8479208].
Korponay-Szabo I R, Dahlbom I, Laurila K, et al. Elevation of IgG antibodies against tissue transglutaminase as a diagnostic tool for coeliac disease in selective IgA deficiency. Gut. 2003;52(11):1567-1571. No prevalence or incidence reported. [pmid: 14570724]. [pmcid: 1773847].
Korponay-Szabo I R, Kovacs J B, Czinner A, et al. High prevalence of silent celiac disease in preschool children screened with IgA/IgG antiendomysium antibodies. J Pediatr Gastroenterol Nutr. 1999;28(1):26-30. Not a relevant screening geography. [pmid: 9890464].
Korponay-Szabo I R, Kovacs J B, Lorincz M, et al. Prospective significance of antiendomysium antibody positivity in subsequently verified celiac disease. J Pediatr Gastroenterol Nutr. 1997;25(1):56-63. No prevalence or incidence reported. [pmid: 9226528].
Kosnai I, Kuitunen P, Siimes M A. Iron deficiency in children with coeliac disease on treatment with gluten-free diet. Role of intestinal blood loss. Arch Dis Child. 1979;54(5):375-378. No prevalence or incidence reported. [pmid: 314273].
Kotaniemi-Syrjanen Anne, Reijonen Tiina M, Romppanen Jarkko, et al. Allergen-specific immunoglobulin E antibodies in wheezing infants: the risk for asthma in later childhood. Pediatrics. 2003;111(3):E255-E261. No prevalence or incidence reported. [pmid: 12612281].
Kowalska E, Wasowska-Krolikowska K, Toporowska-Kowalska E. Estimation of antithyroid antibodies occurrence in children with coeliac disease. Medical Science Monitor - International Medical Journal of Experimental and Clinical Research. 2000;6(4):719-721. No prevalence or incidence reported. [pmid: 11208398].
Kowlessar O D, Phillips L D. Celiac disease. Med Clin North Am. 1970;54(3):647-656. No prevalence or incidence reported. [pmid: 5423138].
Kristensen M, Lenz K, Nielsen O V, et al. Short bowel syndrome following resection for Crohn's disease. Scand J Gastroenterol. 1974;9(6):559-565. No prevalence or incidence reported. [pmid: 4424368].
Kristiansson B, Karlberg J, Fallstrom S P. Infants with low rate of weight gain. I. A study of organic factors and growth patterns. Acta Paediatr Scand. 1981;70(5):655-662. No prevalence or incidence reported. [pmid: 7324913].
Kuc caron, Novakova D, Be caron, et al. Gliadin, endomysial and thyroid antibodies in patients with latent autoimmune diabetes of adults (LADA). Clin Exp Immunol. 2003;133(1):139-143. No prevalence or incidence reported. [pmid: 12823288]. [pmcid: 1808742].
Kucera P, Novakova D, Behanova M, et al. Gliadin, endomysial and thyroid antibodies in patients with latent autoimmune diabetes of adults (LADA). Clin Exp Immunol. 2003;133(1):139-143. No prevalence or incidence reported. [pmid: 12823288]. [pmcid: 1808742].
Kuitunen Mikael, Saukkonen Tero, Ilonen Jorma, et al. Intestinal permeability to mannitol and lactulose in children with type 1 diabetes with the HLA-DQB1*02 allele. Autoimmunity. 2002;35(5):365-368. No prevalence or incidence reported. [pmid: 12515291].
Kuitunen P, Kosnai I, Savilahti E. Morphometric study of the jejunal mucosa in various childhood enteropathies with special reference to intraepithelial lymphocytes. J Pediatr Gastroenterol Nutr. 1982;1(4):525-531. No prevalence or incidence reported. [pmid: 7186067].
Kulig M, Bergmann R, Niggemann B, et al. Prediction of sensitization to inhalant allergens in childhood: evaluating family history, atopic dermatitis and sensitization to food allergens. The MAS Study Group. Multicentre Allergy Study. Clinical and Experimental Allergy - Journal of the British Society for Allergy and Clinical Immunology. 1998;28(11):1397-1403. No prevalence or incidence reported. [pmid: 9824413].
Kulig M, Bergmann R, Tacke U, et al. Long-lasting sensitization to food during the first two years precedes allergic airway disease. The MAS Study Group, Germany. Pediatric Allergy and Immunology - Official Publication of the European Society of Pediatric Allergy and Immunology. 1998;9(2):61-67. No prevalence or incidence reported. [pmid: 9677600].
Kull K, Uibo O, Salupere R, et al. High frequency of antigliadin antibodies and absence of antireticulin and antiendomysium antibodies in patients with ulcerative colitis. J Gastroenterol. 1999;34(1):61-65. No prevalence or incidence reported. [pmid: 10204612].
Kumar P J, Walker-Smith J, Milla P, et al. The teenage coeliac: follow up study of 102 patients. Arch Dis Child. 1988;63(8):916-920. No prevalence or incidence reported. [pmid: 3415327].
Kumar P J. European and North American populations should be screened for coeliac disease. Gut. 2003;52(2):170-171. No prevalence or incidence reported. [pmid: 12692052]. [pmcid: 1774950].
Kumar P, Bartram C I. Relevance of the barium follow-through examination in the diagnosis of adult celiac disease. Gastrointest Radiol. 1979;4(3):285-289. No prevalence or incidence reported. [pmid: 556235].
Kumar P, Clark M. Primary biliary cirrhosis and coeliac disease. Is there an association?. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(4):248-250. No prevalence or incidence reported. [pmid: 12038807].
Kumar R, Lumsden A, Ciclitira P J, et al. Human genome search in celiac disease using gliadin cDNA as probe. J Mol Biol. 2000;300(5):1155-1167. No prevalence or incidence reported. [pmid: 10903861].
Kumar Rajesh, Eastwood Amy L, Brown Milton L, et al. Human genome search in celiac disease: mutated gliadin T-cell-like epitope in two human proteins promotes T-cell activation. J Mol Biol. 2002;319(3):593-602. No prevalence or incidence reported. [pmid: 12054857].
Kumar V, Lerner A, Valeski J E, et al. Endomysial antibodies in the diagnosis of celiac disease and the effect of gluten on antibody titers. Immunol Invest. 1989;18(14):533-544. No prevalence or incidence reported. [pmid: 2499536].
Kumar V, Rajadhyaksha M, Wortsman J. Celiac disease-associated autoimmune endocrinopathies. Clin Diagn Lab Immunol. 2001;8(4):678-685. No prevalence or incidence reported. [pmid: 11427410]. [pmcid: 96126].
Kuscu N K, Akcali S, Kucukmetin N T. Celiac disease and polycystic ovary syndrome. International Journal of Gynaecology and Obstetrics- the Official Organ of the International Federation of Gynaecology and Obstetrics. 2002;79(2):149-150. No prevalence or incidence reported. [pmid: 12427401].
La Seta F, Salerno G, Buccellato A, et al. Radiographic indicants of adult celiac disease assessed by double-contrast small bowel enteroclysis. Eur J Radiol. 1992;15(2):157-162. No prevalence or incidence reported. [pmid: 1425755].
Labate A, Gambardella A, Messina D, et al. Silent celiac disease in patients with childhood localization-related epilepsies. Epilepsia. 2001;42(9):1153-1155. No prevalence or incidence reported. [pmid: 11580763].
Lad R, Jacobson K. The changing face of celiac disease. Paediatr Child Health. 2001;6(9):644-651. No prevalence or incidence reported. [pmid: 20084136].
Laghi A, Paolantonio P, Catalano C, et al. Original report. MR imaging of the small bowel using polyethylene glycol solution as an oral contrast agent in adults and children with celiac disease: Preliminary observations. Am J Roentgenol. 2003;180(1):191-194. No prevalence or incidence reported. [pmid: 12490501].
Lahat E, Broide E, Leshem M, et al. Prevalence of celiac antibodies in children with neurologic disorders. Pediatr Neurol. 2000;22(5):393-396. No prevalence or incidence reported. [pmid: 10913732].
Lahdeaho M L, Lehtinen M, Rissa H R, et al. Antipeptide antibodies to adenovirus E1b protein indicate enhanced risk of celiac disease and dermatitis herpetiformis. Int Arch Allergy Immunol. 1993;101(3):272-276. No prevalence or incidence reported. [pmid: 8324388].
Lakatos L, Pandur T, David G, et al. Association of extraintestinal manifestations of inflammatory bowel disease in a province of western Hungary with disease phenotype: Results of a 25-year follow-up study. World J Gastroenterol. 2003;9(10):2300-2307. No prevalence or incidence reported. [pmid: 14562397].
Lampasona V, Bazzigaluppi E, Barera G, et al. Tissue transglutaminase and combined screening for coeliac disease and type 1 diabetes-associated autoantibodies. Lancet. 1998;352(9135):1192-1193. No prevalence or incidence reported. [pmid: 9777840].
Lancaster Smith M J, Perrin J, Swarbrick E T, et al. Coeliac disease and autoimmunity. Postgrad Med J. 1974;50(579):45-48. No prevalence or incidence reported. [pmid: 4618907].
Langman M J, Banwell J G, Stewart J S, et al. ABO blood groups, secretor status, and intestinal alkaline phosphatase concentrations in patients with celiac disease. Gastroenterology. 1969;57(1):19-23. No prevalence or incidence reported. [pmid: 5788646].
Langman M J, McConnell T H, Spiegelhalter D J, et al. Changing patterns of coeliac disease frequency: an analysis of Coeliac Society membership records. Gut. 1985;26(2):175-178. No prevalence or incidence reported. [pmid: 3967836]. [pmcid: 1432428].
Langman M J. Can epidemiology help us prevent celiac disease?. Gastroenterology. 1986;90(2):489-491. No prevalence or incidence reported. [pmid: 3484457].
Langman M J. Epidemiology of cancer of the oesophagus and stomach. Br J Surg. 1971;58(10):792-793. No prevalence or incidence reported. [pmid: 4938430].
Langman M J. Recent changes in the patterns of chronic digestive disease in the United Kingdom. Postgrad Med J. 1984;60(709):733-736. No prevalence or incidence reported. [pmid: 6504802].
Lang-Muritano M, Molinari L, Dommann-Scherrer C, et al. Incidence of enteropathy-associated T-cell lymphoma in celiac disease: Implications for children and adolescents with type 1 diabetes. Pediatr Diabetes. 2002;3(1):42-45. No prevalence or incidence reported. [pmid: 15016174].
Lankisch P G, Martinez Schramm A, Petersen F, et al. Diagnostic intervals for recognizing celiac disease. Z Gastroenterol. 1996;34(8):473-477. No prevalence or incidence reported. [pmid: 8794542].
Lanning M, Kouvalainen K, Simila S, et al. Agammaglobulinemia with arthritis and celiac disease developing after infectious mononucleosis. Follow up study of a case. Scand J Infect Dis. 1977;9(2):144-148. No prevalence or incidence reported. [pmid: 302479].
Larizza D, Calcaterra V, De Giacomo C, et al. Celiac disease in children with autoimmune thyroid disease. Eur J Pediatr. 2001;139(5):738-740. No prevalence or incidence reported.
Larizza D, Calcaterra V, Luinetti O, et al. Evidence for immunogenetic predisposition in children with celiac disease and autoimmune thyroid disease. Int J Med Biol Environ. 2001;29(2):143-148. No prevalence or incidence reported.
Larizza D, Locatelli M, Vitali L, et al. Serum liver enzymes in Turner syndrome. Eur J Pediatr. 2000;159(3):143-148. No prevalence or incidence reported. [pmid: 10664223].
Laron Z, Kiess W, Phillip M. Foreword. Journal of Pediatric Endocrinology & Metabolism - Jpem. 2001;14(Suppl 1):571. No prevalence or incidence reported.
Larrick J W. The polymerase chain reaction: A novel method for the study of mutation and polymorphism in the human population. Clin Ecol. 1987;5(4):159-165. No prevalence or incidence reported.
Lasch E E, Ramot B, Neumann G. Childhood celiac disease in Israel. Epidemiological aspects. Isr J Med Sci. 1968;4(6):1260-1264. Not a relevant screening geography. [pmid: 5728813].
Laurin P, Falth-Magnusson K, Sundqvist T. Increase in nitric oxide urinary products during gluten challenge in children with coeliac disease. Scand J Gastroenterol. 2003;38(1):55-60. No prevalence or incidence reported. [pmid: 12608465].
Lawrence J S. Hypogammaglobulinaemia in the United Kingdom. IV. Rheumatic disease in hypogammaglobulinaemia patients and their relatives. Special Report Series,.Medical Research Council (Great Britain) 1971;31035–44. No prevalence or incidence reported
Le Clainche L, Le Bourgeois M, Fauroux B, et al. Long-term outcome of idiopathic pulmonary hemosiderosis in children. Medicine. 2000;79(5):318-326. No prevalence or incidence reported. [pmid: 11039080].
Le Quellec A, Clapie M, Callamand P, et al. Circulating oxyntomodulin-like immunoreactivity in healthy children and children with celiac disease. J Pediatr Gastroenterol Nutr. 1998;27(5):513-518. No prevalence or incidence reported. [pmid: 9822314].
Lebenthal E, Branski D. Childhood celiac disease: A reappraisal. Eur J Pediatr. 1981;98(5):681-690. No prevalence or incidence reported.
Lebenthal Emanuel, Branski David. Celiac disease: an emerging global problem. J Pediatr Gastroenterol Nutr. 2002;35(4):472-474. No prevalence or incidence reported. [pmid: 12394370].
Lee F I, Prior J, Murray S M. Celiac disease in monozygous twin boys. Asynchronous presentation. Dig Dis Sci. 1982;27(12):1137-1140. No prevalence or incidence reported. [pmid: 6890892].
Lee J K, Marcos H B, Semelka R C. MR imaging of the small bowel using the HASTE sequence. Ajr. American Journal of Roentgenology. 1998;170(6):1457-1463. No prevalence or incidence reported. [pmid: 9609153].
Lee M F. The diagnosis of steatorrhoea in outpatients. Br J Surg. 1970;57(5):387-388. No prevalence or incidence reported. [pmid: 4193530].
Lee Susie K, Lo Winson, Memeo Lorenzo, et al. Duodenal histology in patients with celiac disease after treatment with a gluten-free diet. Gastroenterol Int. 2003;57(2):187-191. No prevalence or incidence reported.
Leech S. Molecular mimicry in autoimmune disease. Arch Dis Child. 1998;79(5):448-451. No prevalence or incidence reported. [pmid: 10193262].
Lehto M, Palosuo K, Varjonen E, et al. Humoral and cellular responses to gliadin in wheat-dependent, exercise-induced anaphylaxis. Clinical and Experimental Allergy - Journal of the British Society for Allergy and Clinical Immunology. 2003;33(1):90-95. No prevalence or incidence reported. [pmid: 12534555].
Lejarraga H, Caino S, Salvador A, et al. Normal growth velocity before diagnosis of celiac disease. J Pediatr Gastroenterol Nutr. 2000;30(5):552-556. No prevalence or incidence reported. [pmid: 10817287].
Lembcke B, Schneider H, Lankisch P G. Is the assay of disaccharidase activity in small bowel mucosal biopsy relevant for clinical gastroenterologists?. Klin Wochenschr. 1989;67(11):568-575. No prevalence or incidence reported. [pmid: 2747134].
Lemieux B, Boivin M, Brossard J H, et al. Normal parathyroid function with decreased bone mineral density in treated celiac disease. Can J Gastroenterol. 2001;15(5):302-307. No prevalence or incidence reported. [pmid: 11381297].
Lenander-Lumikari M, Ihalin R, Lahteenoja H. Changes in whole saliva in patients with coeliac disease. Arch Oral Biol. 2000;45(5):347-354. No prevalence or incidence reported. [pmid: 10739855].
Leon F, Camarero C, Pena R, et al. Anti-transglutaminase IgA ELISA: clinical potential and drawbacks in celiac disease diagnosis. Scand J Gastroenterol. 2001;36(8):849-853. No prevalence or incidence reported. [pmid: 11495081].
Leonard J N, Tucker W F, Fry J S, et al. Increased incidence of malignancy in dermatitis herpetiformis. Br Med J (Clin Res Ed). 1983;286(6358):16-18. No prevalence or incidence reported. [pmid: 6401441].
Lepage V, Lamm L U, Charron D. Molecular aspects of HLA class II and some autoimmune diseases. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1993;20(3):153-164. No prevalence or incidence reported. [pmid: 8338813].
Lepore L, Martelossi S, Pennesi M, et al. Prevalence of celiac disease in patients with juvenile chronic arthritis. Eur J Pediatr. 1996;129(2):311-313. No prevalence or incidence reported.
Lepore L, Pennesi M, Ventura A, et al. Anti-alpha-gliadin antibodies are not predictive of celiac disease in juvenile chronic arthritis. Acta Paediatr. 1993;82(67):569-573. No prevalence or incidence reported. [pmid: 8338992].
Lerner A, Blank M, Lahat N, et al. Increased prevalence of autoantibodies in celiac disease. Dig Dis Sci. 1998;43(4):723-726. No prevalence or incidence reported. [pmid: 9558026].
Lerner A. Factors affecting the clinical presentation and time of diagnosis of celiac disease: the Jerusalem and the West Bank-Gaza experience. Isr J Med Sci. 1994;30(4):294-295. No prevalence or incidence reported. [pmid: 8050879].
Leslie D, Lipsky P, Louis Notkins A. Autoantibodies as predictors of disease. J Clin Invest. 2001;108(10):1417-1422. No prevalence or incidence reported. [pmid: 11714731]. [pmcid: 209428].
Lesort M, Chun W, Johnson G V, et al. Tissue transglutaminase is increased in Huntington's disease brain. J Neurochem. 1999;73(5):2018-2027. No prevalence or incidence reported. [pmid: 10537061].
Lesort M, Tucholski J, Miller M L, et al. Tissue transglutaminase: a possible role in neurodegenerative diseases. Prog Neurobiol. 2000;61(5):439-463. No prevalence or incidence reported. [pmid: 10748319].
Lesort Mathieu, Chun WanJoo, Tucholski Janusz, et al. Does tissue transglutaminase play a role in Huntington's disease?. Neurochem Int. 2002;40(1):37-52. No prevalence or incidence reported. [pmid: 11738472].
Leth R D, Abrahamsson H, Kilander A, et al. Malabsorption of fat after partial gastric resection. A study of pathophysiologic mechanisms. Eur J Surg. 1991;157(3):205-208. No prevalence or incidence reported. [pmid: 1678631].
Levin D C, Baltaxe H A. High incidence of celiac axis narrowing in asymptomatic individuals. Am J Roentgenol Radium Ther Nucl Med. 1972;116(2):426-429. No prevalence or incidence reported. [pmid: 5078866].
Levine A, Bujanover Y, Reif S, et al. Comparison of assays for anti-endomysial and anti-transglutaminase antibodies for diagnosis of pediatric celiac disease. Israel Medical Association Journal - Imaj. 2000;2(2):122-125. No prevalence or incidence reported.
Levine A, Lahav J, Zahavi I, et al. Activated protein C resistance in pediatric inflammatory bowel disease. J Pediatr Gastroenterol Nutr. 1998;26(2):172-174. No prevalence or incidence reported. [pmid: 9481632].
Lewis W H, Imber W E. Allergy epidemiology in the St. Louis, Missouri, area. V. Cereal ingestants. Ann Allergy. 1975;35(4):251-254. No prevalence or incidence reported. [pmid: 1181949].
Lie B A, Sollid L M, Ascher H, et al. A gene telomeric of the HLA class I region is involved in predisposition to both type 1 diabetes and coeliac disease. Tissue Antigens. 1999;54(2):162-168. No prevalence or incidence reported. [pmid: 10488743].
Lifschitz C H, Polanco I, Lobb K. The urinary excretion of polyethylene glycol as a test for mucosal integrity in children with celiac disease: comparison with other noninvasive tests. J Pediatr Gastroenterol Nutr. 1989;9(1):49-57. No prevalence or incidence reported. [pmid: 2778569].
Lifshitz F, Tarim O. Nutritional dwarfing. Curr Probl Pediatr. 1993;23(8):322-336. No prevalence or incidence reported. [pmid: 8252932].
Lightdale C J, Winawer S J. Screening diagnosis and staging of esophageal cancer. Semin Oncol. 1984;11(2):101-112. No prevalence or incidence reported. [pmid: 6729490].
Lim S G, Menzies I S, Lee C A, et al. Intestinal permeability and function in patients infected with human immunodeficiency virus. A comparison with coeliac disease. Scand J Gastroenterol. 1993;28(7):573-580. No prevalence or incidence reported. [pmid: 8362208].
Lin H J, Rotter J I, Conte W J. Use of HLA marker associations and HLA haplotype linkage to estimate disease risks in families with gluten-sensitive enteropathy. Clin Genet. 1985;28(3):185-198. No prevalence or incidence reported. [pmid: 3877582].
Lindberg J, Ahren C, Iwarson S. Intestinal villous atrophy in chronic active hepatitis. Scand J Gastroenterol. 1979;14(8):1015-1018. No prevalence or incidence reported. [pmid: 531508].
Lindblad A, Glaumann H, Strandvik B. Natural history of liver disease in cystic fibrosis. Hepatology. 1999;30(5):1151-1158. No prevalence or incidence reported. [pmid: 10534335].
Linder J, Cheruvattath R, Truss C, et al. Diagnostic yield and clinical implications of push enteroscopy: Results from a nonspecialized center. J Clin Gastroenterol. 2002;35(5):383-386. No prevalence or incidence reported. [pmid: 12394225].
Lindgren S, Sjoberg K, Eriksson S. Unsuspected coeliac disease in chronic ‘cryptogenic’ liver disease. Scand J Gastroenterol. 1994;29(7):661-664. No prevalence or incidence reported. [pmid: 7939405].
Lindquist B L, Rogozinski T, Moi H, et al. Endomysium and gliadin IgA antibodies in children with coeliac disease. Scand J Gastroenterol. 1994;29(5):452-456. No prevalence or incidence reported. [pmid: 8036461].
Lindqvist U, Rudsander A, Bostrom A, et al. IgA antibodies to gliadin and coeliac disease in psoriatic arthritis. Rheumatology (Oxford). 2002;41(1):31-37. No prevalence or incidence reported. [pmid: 11792877].
Little A-M, Stern P L. Does HLA type predispose some individuals to cancer?. Mol Med Today. 1999;5(8):337-342. No prevalence or incidence reported. [pmid: 10431166].
Little T M. Immunoglobulin levels in families with coeliac disease. Lancet. 1972;2(7774):400-401. No prevalence or incidence reported. [pmid: 4117714].
Littlewood J M. Coeliac disease in childhood. Bailliere's Clinical Gastroenterology. 1995;9(2):295-327. No prevalence or incidence reported. [pmid: 7549029].
Liu A H, Murphy J R. Hygiene hypothesis: Fact or fiction?. J Allergy Clin Immunol. 2003;111(3):471-478. No prevalence or incidence reported. [pmid: 12642824].
Liu E, Bao F, Barriga K, et al. Fluctuating transglutaminase autoantibodies are related to histologic features of celiac disease. Clin Gastroenterol Hepatol. 2003;1(5):356-362. No prevalence or incidence reported. [pmid: 15017653].
Liu Edwin, Eisenbarth George S. Type 1A diabetes mellitus-associated autoimmunity. Endocrinol Metab Clin North Am 2002;31(2):391–410, Vii. No prevalence or incidence reported
Liu Jianjun, Juo Suh, Holopainen Paivi, et al. Genomewide linkage analysis of celiac disease in Finnish families. Am J Hum Genet. 2002;70(1):51-59. No prevalence or incidence reported. [pmid: 11715113]. [pmcid: 384903].
Ljungman G, Myrdal U. Compliance in teenagers with coeliac disease--a Swedish follow-up study. Acta Paediatr. 1993;82(3):235-238. No prevalence or incidence reported. [pmid: 8495075].
Lloyd J K. Dietary problems associated with the care of chronically sick children. J Hum Nutr. 1979;33(2):135-139. No prevalence or incidence reported. [pmid: 438509].
Lloyd J K. Effects and treatment of malabsorption in childhood. Proc Nutr Soc. 1972;31(1):61-66. No prevalence or incidence reported. [pmid: 5048485].
Lloyd-Still J D, Shwachman H. Duodenal microflora: a prospective study in pediatric gastrointestinal disorders. Am J Dig Dis. 1975;20(8):708-715. No prevalence or incidence reported. [pmid: 1098448].
Lloyd-Still J D. Chronic diarrhea of childhood and the misuse of elimination diets. Eur J Pediatr. 1979;95(1):10-13. No prevalence or incidence reported.
Lloyd-Still J D. Where have all the celiacs gone?. Pediatrics. 1978;61(6):929-930. No prevalence or incidence reported. [pmid: 673561].
Lo Winson, Sano Kevin, Lebwohl Ben, et al. Changing presentation of adult celiac disease. Dig Dis Sci. 2003;48(2):395-398. No prevalence or incidence reported. [pmid: 12643621].
Lofgren J, Jarnerot G, Danielsson D, et al. Incidence and prevalence of primary biliary cirrhosis in a defined population in Sweden. Scand J Gastroenterol. 1985;20(5):647-650. No prevalence or incidence reported. [pmid: 4023628].
Loft D E, Marsh M N, Crowe P T. Rectal gluten challenge and diagnosis of coeliac disease. Lancet. 1990;335(8701):1293-1295. No prevalence or incidence reported. [pmid: 1976971].
Loft D E. The epidemiology and diagnosis of coeliac disease. Eur J Gastroenterol Hepatol. 1993;5(2):69-72. No prevalence or incidence reported.
Logan J S. The relation of meat-eating to the incidence and severity of sprue and the relation of sprue to diarrhoea in the United Kingdom. Ulster Med J. 1971;40(2):151-157. No prevalence or incidence reported. [pmid: 5150064].
Logan R F, Rifkind E A, Busuttil A, et al. Prevalence and “incidence” of celiac disease in Edinburgh and the Lothian region of Scotland. Gastroenterology. 1986;90(2):334-342. Serology screen <1990. [pmid: 3484455].
Logan R F, Rifkind E A, Turner I D, et al. Mortality in celiac disease. Gastroenterology. 1989;97(2):265-271. No prevalence or incidence reported. [pmid: 2744350].
Logan R F, Tucker G, Rifkind E A, et al. Changes in clinical features of coeliac disease in adults in Edinburgh and the Lothians 1960-79. Br Med J (Clin Res Ed). 1983;286(6359):95-97. Serology screen <1990. [pmid: 6401509].
Logan R F. Screening for coeliac disease--has the time come for mass screening?. Acta Paediatr. 1996;412(Suppl):15-19. No prevalence or incidence reported.
Lohiniemi S, Maki M, Kaukinen K, et al. Gastrointestinal symptoms rating scale in coeliac disease patients on wheat starch-based gluten-free diets. Scand J Gastroenterol. 2000;35(9):947-949. No prevalence or incidence reported. [pmid: 11063154].
Lomoschitz F, Schima W, Schober E, et al. Enteroclysis in adult celiac disease: diagnostic value of specific radiographic features. Eur Radiol. 2002;13(4):890-896. No prevalence or incidence reported. [pmid: 12664131].
Londei M. The external world of gluten and autoimmunity. Gut. 2001;49(4):463-464. No prevalence or incidence reported. [pmid: 11559639]. [pmcid: 1728462].
Long R G, Wills M R. Hepatic osteodystrophy. Br J Hosp Med. 1978;20(3):312-321. No prevalence or incidence reported. [pmid: 708974].
Lonnerdal B, Dewey K G. Epidemiology of iron deficiency in infants and children. Ann Nestle. 1995;53(1):11-17. No prevalence or incidence reported.
Lopez-Vazquez A, Rodrigo L, Fuentest D, et al. MHC class I chain related gene A (MICA) modulates the development of coeliac disease in patients with the high risk heterodimer DQA1*0501/DQB1*0201. Gut. 2002;50(3):336-340. No prevalence or incidence reported. [pmid: 11839711]. [pmcid: 1773124].
Lopez-Vazquez Antonio, Rodrigo Luis, Fuentes Dolores, et al. MICA-A5.1 allele is associated with atypical forms of celiac disease in HLA-DQ2-negative patients. Immunogenetics. 2002;53(1011):989-991. No prevalence or incidence reported. [pmid: 11862400].
Lorber M, Gershwin M E, Shoenfeld Y. The coexistence of systemic lupus erythematosus with other autoimmune diseases: The kaleidoscope of autoimmunity. Semin Arthritis Rheum. 1994;24(2):105-113. No prevalence or incidence reported. [pmid: 7839152].
Lorini R, Scaramuzza A, Vitali L, et al. Clinical aspects of coeliac disease in children with insulin-dependent diabetes mellitus. Journal of Pediatric Endocrinology & Metabolism - Jpem. 1996;9(Suppl 1):101-111. No prevalence or incidence reported. [pmid: 8887160].
Louis E J, Thomson G, Payami H. The affected sib method. II. The intermediate model. Ann Hum Genet. 1983;47(3):225-243. No prevalence or incidence reported. [pmid: 6688509].
Louka A S, Moodie S J, Karell K, et al. A collaborative European search for non-DQA1 *05-DQB1 *02 Celiac disease loci on HLA-Dr3 haplotypes: Analysis of transmission from homozygous parents. Hum Immunol. 2003;64(3):350-358. No prevalence or incidence reported. [pmid: 12651074].
Louka A S, Nilsson S, Olsson M, et al. HLA in coeliac disease families: a novel test of risk modification by the ‘other’ haplotype when at least one DQA1*05-DQB1*02 haplotype is carried. Tissue Antigens. 2002;60(2):147-154. No prevalence or incidence reported. [pmid: 12392509].
Louka A S, Stensby E K, Ek J, et al. Coeliac disease candidate genes: no association with functional polymorphisms in matrix metalloproteinase 1 and 3 gene promoters. Scand J Gastroenterol. 2002;37(8):931-935. No prevalence or incidence reported. [pmid: 12229968].
Louka A S, Torinsson Naluai A, D'Alfonso S, et al. The IL12B gene does not confer susceptibility to coeliac disease. Tissue Antigens. 2002;59(1):70-72. Not sensitivity or specificity of an identified test. [pmid: 11972887].
Lowenstein H, Krasilnikoff P A, Bjerrum O J, et al. Occurrence of specific precipitins against bovine whey proteins in serum from children with gastrointestinal disorders. Int Arch Allergy Appl Immunol. 1977;55(16):514-525. No prevalence or incidence reported. [pmid: 563380].
Lubrano E, Ciacci C, Ames P R J, et al. The arthritis of coeliac disease: Prevalence and pattern in 200 adult patients. Br J Rheumatol. 1996;35(12):1314-1318. No prevalence or incidence reported. [pmid: 9010064].
Ludvigsson J F, Falth-Magnusson K, Ludvigsson J. Tissue transglutaminase auto-antibodies in cord blood from children to become celiacs. Scand J Gastroenterol. 2001;36(12):1279-1283. No prevalence or incidence reported. [pmid: 11761017].
Ludvigsson J F, Ludvigsson J. Coeliac disease in the father affects the newborn. Gut. 2001;49(2):169-175. No prevalence or incidence reported. [pmid: 11454790]. [pmcid: 1728412].
Ludvigsson J F, Ludvigsson J. Stressful life events, social support and confidence in the pregnant woman and risk of coeliac disease in the offspring. Scand J Gastroenterol. 2003;38(5):516-521. No prevalence or incidence reported. [pmid: 12795462].
Ludvigsson J F. Effect of gastroenteritis during pregnancy on neonatal outcome. European Journal of Clinical Microbiology & Infectious Diseases - Official Publication of the European Society of Clinical Microbiology. 2001;20(12):843-849. No prevalence or incidence reported. [pmid: 11837634].
Luostarinen L K, Collin P O, Peraaho M J, et al. Coeliac disease in patients with cerebellar ataxia of unknown origin. Ann Med. 2001;33(6):445-449. No prevalence or incidence reported. [pmid: 11585106].
Luostarinen L, Dastidar P, Collin P, et al. Association between coeliac disease, epilepsy and brain atrophy. Eur Neurol. 2001;46(4):187-191. No prevalence or incidence reported. [pmid: 11721124].
Luostarinen L, Himanen S-L, Luostarinen M, et al. Neuromuscular and sensory disturbances in patients with well treated coeliac disease. J Neurol Neurosurg Psychiatry. 2003;74(4):490-494. No prevalence or incidence reported. [pmid: 12640070].
Luostarinen L, Pirttila T, Collin P. Coeliac disease presenting with neurological disorders. Eur Neurol. 1999;42(3):132-135. No prevalence or incidence reported. [pmid: 10529537].
Lutwak L. Symposium on osteoporosis. Nutritional aspects of osteoporosis. J Am Geriatr Soc. 1969;17(2):115-119. No prevalence or incidence reported. [pmid: 5763687].
Luzi Giuseppe, Zullo Angelo, Iebba Filippo, et al. Duodenal pathology and clinical-immunological implications in common variable immunodeficiency patients. Am J Gastroenterol. 2003;98(1):118-121. No prevalence or incidence reported. [pmid: 12526946].
Luzza F, Mancuso M, Imeneo M, et al. Helicobacter pylori infection in children with celiac disease: prevalence and clinicopathologic features. J Pediatr Gastroenterol Nutr. 1999;28(2):143-146. No prevalence or incidence reported. [pmid: 10467996].
Lynch H T, Smyrk T C, Lynch P M, et al. Adenocarcinoma of the small bowel in lynch syndrome II. Cancer. 1989;64(10):2178-2183. No prevalence or incidence reported. [pmid: 2804907].
MacFarlane Amanda J, Burghardt Karolina M, Kelly John, et al. A type 1 diabetes-related protein from wheat (Triticum aestivum). cDNA clone of a wheat storage globulin, Glb1, linked to islet damage. J Biol Chem. 2002;278(1):54-63. No prevalence or incidence reported. [pmid: 12409286].
Mackay I R, Morris P J. Association of autoimmune active chronic hepatitis with HL-A1,8. Lancet. 1972;2(7781):793-795. No prevalence or incidence reported. [pmid: 4116233].
Mackey J, Treem W R, Worley G, et al. Frequency of celiac disease in individuals with Down syndrome in the United States. Clin Pediatr (Phila). 2001;40(5):249-252. Not a relevant screening group. [pmid: 11388673].
Mackner L M, McGrath A M, Stark L J. Dietary recommendations to prevent and manage chronic pediatric health conditions: Adherence, intervention, and future directions. J Dev Behav Pediatr. 2001;22(2):130-143. No prevalence or incidence reported. [pmid: 11332783].
Mader R, Adawi M, Schonfeld S. Malabsorption in systemic lupus erythematosus. Clin Exp Rheumatol. 1997;15(6):659-661. No prevalence or incidence reported. [pmid: 9444423].
Madsen C. Prevalence of food allergy/intolerance in Europe. Environ Toxicol Pharmacol. 1997;4(12):163-167. No prevalence or incidence reported.
Magalotti D, Volta U, Bonfiglioli A, et al. Splanchnic haemodynamics in patients with coeliac disease: effects of a gluten-free diet. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2003;35(4):262-268. No prevalence or incidence reported. [pmid: 12801038].
Magnolfi C F, Zani G, Lacava L, et al. Soy allergy in atopic children. Annals of Allergy, Asthma & Immunology - Official Publication of the American College of Allergy, Asthma, & Immunology. 1996;77(3):197-201. No prevalence or incidence reported. [pmid: 8814044].
Magrath G, Hartland B V. Dietary recommendations for children and adolescents with diabetes: An implementation paper. J Hum Nutr Diet. 1993;6(6):491-507. No prevalence or incidence reported.
Magrath G, Hartland B V. Dietary recommendations for children and adolescents with diabetes: an implementation paper. British Diabetic Association's Professional Advisory Committee. Diabetic Medicine - a Journal of the British Diabetic Association. 1993;10(9):874-885. No prevalence or incidence reported. [pmid: 8281737].
Mahadeva S, Wyatt J I, Howdle P D. Is a raised intraepithelial lymphocyte count with normal duodenal villous architecture clinically relevant?. J Clin Pathol. 2002;55(6):424-428. No prevalence or incidence reported. [pmid: 12037023]. [pmcid: 1769667].
Mainardi Elsa, Montanelli Alessandro, Dotti Maria, et al. Thyroid-related autoantibodies and celiac disease: a role for a gluten-free diet?. J Clin Gastroenterol. 2002;35(3):245-248. No prevalence or incidence reported. [pmid: 12192201].
Maki M, Aine L, Lipsanen V, et al. Dental enamel defects in first-degree relatives of coeliac disease patients. Lancet. 1991;337(8744):763-764. No prevalence or incidence reported. [pmid: 1672395].
Maki M, Collin P. Coeliac disease. Lancet. 1997;349(9067):1755-1759. No prevalence or incidence reported. [pmid: 9193393].
Maki M, Hallstrom O, Huupponen T, et al. Increased prevalence of coeliac disease in diabetes. Arch Dis Child. 1984;59(8):739-742. Serology screen <1990. [pmid: 6476871].
Maki M, Huupponen T, Holm K, et al. Seroconversion of reticulin autoantibodies predicts coeliac disease in insulin dependent diabetes mellitus. Gut. 1995;36(2):239-242. Not a relevant screening test. [pmid: 7883223]. [pmcid: 1382410].
Mallas E G, Williamson N, Cooper B T, et al. IgA class reticulin antibodies in relatives of patients with coeliac disease. Gut. 1977;18(8):647-650. Serology screen <1990. [pmid: 892611]. [pmcid: 1411703].
Mallet M. Coeliac disease in the very elderly. Cme J Geriatr Med. 2002;4(2):70-73. Review article.
Maluenda C, Phillips A D, Briddon A, et al. Quantitative analysis of small intestinal mucosa in cow's milk-sensitive enteropathy. J Pediatr Gastroenterol Nutr. 1984;3(3):349-356. No prevalence or incidence reported. [pmid: 6737178].
Mandal A, Mayberry J. How common is celiac disease in South America?. Am J Gastroenterol. 2000;95(3):579-580. No prevalence or incidence reported. [pmid: 10710041].
Mann N S, Mann S K. Celiac sprue and diabetes mellitus. J Clin Gastroenterol. 1993;16(1):4-5. No prevalence or incidence reported. [pmid: 8421143].
Mannell A, van Heerden J A, Weiland L H, et al. Factors influencing survival after resection for ductal adenocarcinoma of the pancreas. Ann Surg. 1986;203(4):403-407. No prevalence or incidence reported. [pmid: 3008674]. [pmcid: 1251125].
Mannion A, Stevens F M, McCarthy C F, et al. Extended major histocompatibility complex haplotypes in celiac patients in the west of Ireland. Am J Med Genet. 1993;45(3):373-377. No prevalence or incidence reported. [pmid: 8434627].
Mantovani V, Corazza G R, Bragliani M, et al. Asp57-negative HLA DQ beta chain and DQA1*0501 allele are essential for the onset of DQw2-positive and DQw2-negative coeliac disease. Clin Exp Immunol. 1993;91(1):153-156. No prevalence or incidence reported. [pmid: 8419077]. [pmcid: 1554651].
Mantovani V, Corazza G R, Frisoni M, et al. HLA-DP polymorphism in northern Italian celiac patients. Tissue Antigens. 1992;40(4):182-186. No prevalence or incidence reported. [pmid: 1361687].
Mariani P, Mazzilli M C, Margutti G, et al. Coeliac disease, enamel defects and HLA typing. Acta Paediatr. 1994;83(12):1272-1275. No prevalence or incidence reported. [pmid: 7734869].
Mariani P, Viti M G, Montuori M, et al. The gluten-free diet: a nutritional risk factor for adolescents with celiac disease?. J Pediatr Gastroenterol Nutr. 1998;27(5):519-523. No prevalence or incidence reported. [pmid: 9822315].
Marin G A, Clark M L, Senior J R. Studies of malabsorption occurring in patients with Laennec's cirrhosis. Gastroenterology. 1969;56(4):727-736. No prevalence or incidence reported. [pmid: 5821080].
Marks D R, Marks L M. Food allergy: Manifestations, evaluation, and management. Postgrad Med. 1993;93(2):191-196201. No prevalence or incidence reported. [pmid: 8433953].
Marks I N, Bank S, Louw J H. Chronic pancreatitis in the Western Cape. Digestion. 1973;9(5):447-453. No prevalence or incidence reported. [pmid: 4784706].
Marks J, Shuster S. Iron metabolism in skin disease. Arch Dermatol. 1968;98(5):469-475. No prevalence or incidence reported. [pmid: 5303116].
Marks J, Shuster S. Vitamin B12 excretion in patients with various skin diseases. Br Med J. 1970;3(723):618-621. No prevalence or incidence reported. [pmid: 5470089]. [pmcid: 1701746].
Marn C S, Gore R M, Ghahremani G G. Duodenal manifestations of nontropical sprue. Gastrointest Radiol. 1986;11(1):30-35. No prevalence or incidence reported. [pmid: 3943675].
Marsh M N, Bjarnason I, Shaw J, et al. Studies of intestinal lymphoid tissue. XIV--HLA status, mucosal morphology, permeability and epithelial lymphocyte populations in first degree relatives of patients with coeliac disease. Gut. 1990;31(1):32-36. No prevalence or incidence reported. [pmid: 2318429]. [pmcid: 1378337].
Marsh M N, Mathan M, Mathan V I. Studies of intestinal lymphoid tissue. VII. The secondary nature of lymphoid cell “activation” in the jejunal lesion of tropical sprue. Am J Pathol. 1983;112(3):302-312. No prevalence or incidence reported. [pmid: 6614143]. [pmcid: 1916392].
Marsh M N. Screening for latent gluten sensitivity: questions many, but answers few. Eur J Gastroenterol Hepatol. 1996;8(1):3-6. No prevalence or incidence reported. [pmid: 8900901].
Marsh M N. Studies of intestinal lymphoid tissue. XI--The immunopathology of cell-mediated reactions in gluten sensitivity and other enteropathies. Scanning Microsc. 1988;2(3):1663-1684. No prevalence or incidence reported. [pmid: 3201202].
Marsh M N. The immunopathology of the small intestinal reaction in gluten-sensitivity. Immunol Invest. 1989;18(14):509-531. No prevalence or incidence reported. [pmid: 2786501].
Marshall C M, Grunow J E. Emesis in infants as a consequence of feedings. Semin Pediatr Surg. 1995;4(3):147-151. No prevalence or incidence reported. [pmid: 7582884].
Martelossi S, Zanatta E, Del Santo E, et al. Dental enamel defects and screening for coeliac disease. Acta Paediatr. 1996;412(Suppl):47-48. No prevalence or incidence reported.
Martinelli P, Troncone R, Paparo F, et al. Coeliac disease and unfavourable outcome of pregnancy. Gut. 2000;46(3):332-335. No prevalence or incidence reported. [pmid: 10673293]. [pmcid: 1727862].
Martinetti M, De Silvestri A, Belloni C, et al. Humoral response to recombinant hepatitis B virus vaccine at birth: Role of HLA and beyond. Clin Immunol. 2000;97(3):234-240. No prevalence or incidence reported. [pmid: 11112362].
Martini Silvia, Mengozzi Giulio, Aimo Giuseppe, et al. Comparative evaluation of serologic tests for celiac disease diagnosis and follow-up. Clin Chem. 2002;48(6 Pt 1):960-963. No prevalence or incidence reported. [pmid: 12029021].
Martin-Villa J M, Lopez-Suarez J C, Perez-Blas M, et al. Coeliac-and enteropathy-associated autoantibodies in Spanish insulin-dependent diabetes mellitus patients and their relation to HLA antigens. J Diabetes Complications. 2001;15(1):38-43. No prevalence or incidence reported. [pmid: 11259925].
Martucci S, Biagi F, Di Sabatino A, et al. Coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(Suppl 2):150-153. No prevalence or incidence reported. [pmid: 12408460].
Masala S, Annibale B, Fiori R, et al. DXA vs. QCT for subclinical celiac disease patients. Acta Diabetol Lat 2003;40(Suppl 1):S174-S176. No prevalence or incidence reported.
Masoero G, Andriulli A, Santini B, et al. Serum trypsinlike immunoreactivity in cystic fibrosis. An aid in assessing progressive involvement of the pancreas. Am J Dis Child. 1983;137(2):167-170. No prevalence or incidence reported. [pmid: 6849303].
Matek Z, Jungvirth-Hegedus M, Kolacek S. Epidemiology of coeliac disease in children in one Croatian county: possible factors that could affect the incidence of coeliac disease and adherence to a gluten-free diet (Part II). Coll Antropol. 2000;24(2):397-404. Not a relevant screening geography. [pmid: 11216408].
Matek Z, Jungvirth-Hegedus M, Kolacek S. Epidemiology of coeliac disease in children in one Croatian county: the cumulative incidence over ten-year period and the way of clinical presentation (Part I). Coll Antropol. 1999;23(2):621-628. Not a relevant screening geography. [pmid: 10646237].
Mathan V I, Baker S J. Epidemic tropical sprue and other epidemics of diarrhea in South Indian villages. Am J Clin Nutr. 1968;21(9):1077-1087. No prevalence or incidence reported. [pmid: 5675861].
Mathus-Vliegen E M H. Lymphoma in coeliac disease. J R Soc Med. 1995;88(12):672-677. No prevalence or incidence reported. [pmid: 8786586]. [pmcid: 1295407].
Mathus-Vliegen E M, Van Halteren H, Tytgat G N. Malignant lymphoma in coeliac disease: various manifestations with distinct symptomatology and prognosis?. J Intern Med. 1994;236(1):43-49. No prevalence or incidence reported. [pmid: 8021572].
Matteoni C A, Goldblum J R, Wang N, et al. Celiac disease is highly prevalent in lymphocytic colitis. J Clin Gastroenterol. 2001;32(3):225-227. No prevalence or incidence reported. [pmid: 11246349].
Mattera D, Sollazzo R, Sarrantonio G, et al. Serum iron, serum ferritin and oral ion load in coeliac patients on a free diet. Ital J Gastroenterol. 1988;20(3):120-124. No prevalence or incidence reported.
Matteucci E, Cinapri V, Quilici S, et al. Screening for coeliac disease in families of adults with Type 1 diabetes based on serological markers. Diabetes Nutr Metab. 2001;14(1):37-42. Not a relevant screening group. [pmid: 11345164].
Maurino E, Capizzano H, Niveloni S, et al. Value of endoscopic markers in celiac disease. Dig Dis Sci. 1993;38(11):2028-2033. No prevalence or incidence reported. [pmid: 8223077].
Maurino Eduardo, Niveloni Sonia, Chernavsky Alejandra, et al. Azathioprine in refractory sprue: results from a prospective, open-label study. Am J Gastroenterol. 2002;97(10):2595-2602. No prevalence or incidence reported. [pmid: 12385445].
Mautalen C, Gonzalez D, Mazure R, et al. Effect of treatment on bone mass, mineral metabolism, and body composition in untreated celiac disease patients. Am J Gastroenterol. 1997;92(2):313-318. No prevalence or incidence reported. [pmid: 9128314].
Mautner V, Steinthorsdottir V, Bailey A. Enteric adenoviruses. Curr Top Microbiol Immunol. 1995;199(III):229-282. No prevalence or incidence reported. [pmid: 7555079].
Mayberry J F, Smart H L, Toghill P J. Familial association between coeliac disease and ulcerative colitis: preliminary communication. J R Soc Med. 1986;79(4):204-205. No prevalence or incidence reported. [pmid: 3701765]. [pmcid: 1290274].
Mazure R M, Vazquez H, Gonzalez D, et al. Early changes of body composition in asymptomatic celiac disease patients. Am J Gastroenterol. 1996;91(4):726-730. No prevalence or incidence reported. [pmid: 8677938].
Mazzacca G. Diet, coeliac disease and gastrointestinal neoplasm. Adv Exp Med Biol 1993;348133–136. No prevalence or incidence reported
Mazzilli M C, Ferrante P, Mariani P, et al. A study of Italian pediatric celiac disease patients confirms that the primary HLA association is to the DQ(alpha 1*0501, beta 1*0201) heterodimer. Hum Immunol. 1992;33(2):133-139. No prevalence or incidence reported. [pmid: 1563982].
Mazzola G, Berrino M, Bersanti M, et al. Immunoglobulin and HLA-DP genes contribute to the susceptibility to juvenile dermatitis herpetiformis. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1992;19(3):129-139. No prevalence or incidence reported. [pmid: 1627534].
Mc Manus R, Wilson A G, Mansfield J, et al. TNF2, a polymorphism of the tumour necrosis-alpha gene promoter, is a component of the celiac disease major histocompatibility complex haplotype. Eur J Immunol. 1996;26(9):2113-2118. No prevalence or incidence reported. [pmid: 8814255].
McCarthy C F. Coeliac disease: its Irish dimensions. Ir J Med Sci. 1975;144(1):1-13. No prevalence or incidence reported. [pmid: 1112676].
McCarthy C F. The incidence of coeliac disease and its familial occurrence. Ir Med J. 1974;67(15):420-421. No prevalence or incidence reported. [pmid: 4374451].
McCarthy D, Manning N, Rees J P, et al. Hypothyroidism and coeliac disease--a family study. Ir J Med Sci. 1976;145(7):237-238. No prevalence or incidence reported. [pmid: 977269].
McCrae W M, Eastwood M A, Martin M R, et al. Neglected coeliac disease. Lancet. 1975;1(7900):187-190. No prevalence or incidence reported. [pmid: 47419].
McCrae W M, Sweet E M. Diagnosis of osteoporosis in childhood. Br J Radiol. 1967;40(470):104-107. No prevalence or incidence reported. [pmid: 6017616].
McCrae W M. Inheritance of coeliac disease. J Med Genet. 1969;6(2):129-131. No prevalence or incidence reported. [pmid: 5801458].
McEvoy A, Dutton J, James O F. Bacterial contamination of the small intestine is an important cause of occult malabsorption in the elderly. Br Med J (Clin Res Ed). 1983;287(6395):789-793. No prevalence or incidence reported. [pmid: 6412829].
McFarlane X A, Bhalla A K, Reeves D E, et al. Osteoporosis in treated adult coeliac disease. Gut. 1995;36(5):710-714. No prevalence or incidence reported. [pmid: 7797121]. [pmcid: 1382674].
McFarlane X A, Bhalla A K, Robertson D A. Effect of a gluten free diet on osteopenia in adults with newly diagnosed coeliac disease. Gut. 1996;39(2):180-184. No prevalence or incidence reported. [pmid: 8991855]. [pmcid: 1383295].
McGowan M, Gibney M J. Calcium intakes in individuals on diets for the management of cows' milk allergy: a case control study. Eur J Clin Nutr. 1993;47(9):609-616. No prevalence or incidence reported. [pmid: 8243425].
McIntyre A S, Ng D P, Smith J A, et al. The endoscopic appearance of duodenal folds is predictive of untreated adult celiac disease. Gastroenterol Int. 1992;38(2):148-151. No prevalence or incidence reported.
McKenna R, Stevens F M, McNicholl B, et al. Family and population studies of HLA and coeliac disease in the West of Ireland. Tissue Antigens. 1983;22(3):175-181. No prevalence or incidence reported. [pmid: 6636110].
McKinley M, Leibowitz S, Bronzo R, et al. Appropriate response to pneumococcal vaccine in celiac sprue. J Clin Gastroenterol. 1995;20(2):113-116. No prevalence or incidence reported. [pmid: 7769189].
McLoughlin R, Sebastian S S, Qasim A, et al. Coeliac disease in Europe. Aliment Pharmacol Ther Suppl. 2003;18(3):45-48. No prevalence or incidence reported.
McMillan S A, Dickey W, Douglas J P, et al. Transthyretin values correlate with mucosal recovery in patients with coeliac disease taking a gluten free diet. J Clin Pathol. 2001;54(10):783-786. No prevalence or incidence reported. [pmid: 11577127]. [pmcid: 1731281].
McMillan S A, Johnston S D, Watson R G, et al. Dietary intake, smoking, and transient anti-gliadin antibodies. Scand J Gastroenterol. 1998;33(5):499-503. No prevalence or incidence reported. [pmid: 9648989].
McNamee S, McLoughlin R, Stevens F M, et al. Coeliac disease in the older patient. Rev Clin Gerontol. 2002;12(2):119-126. No prevalence or incidence reported.
McNeish A S, Anderson C M. Coeliac disease. The disorder in childhood. Clin Gastroenterol. 1974;3(1):127-144. No prevalence or incidence reported. [pmid: 4600388].
McNeish A S, Harms H K, Rey J, et al. The diagnosis of coeliac disease. A commentary on the current practices of members of the European Society for Paediatric Gastroenterology and Nutrition (ESPGAN). Arch Dis Child. 1979;54(10):783-786. No prevalence or incidence reported. [pmid: 507902].
McNeish A S, Sweet E M. Lactose intolerance in childhood coeliac disease. Assessment of its incidence and importance. Arch Dis Child. 1968;43(230):433-437. No prevalence or incidence reported. [pmid: 5666679].
McNicholl B, Egan-Mitchell B, Stevens F, et al. Mucosal recovery in treated childhood celiac disease (gluten-sensitive enteropathy). Eur J Pediatr. 1976;89(3):418-424. No prevalence or incidence reported.
McNicholl B. Coeliac disease: ecology, life history and management. Human Nutrition. Appplied Nutrition. 1986;40(1):55-60. No prevalence or incidence reported.
McNicholl B. Management of coeliac disease. Midwife Health Visit Community Nurse. 1986;22(10):361-364. No prevalence or incidence reported. [pmid: 3641002].
McPherson J R. Jejunal biopsy. Med Clin North Am. 1970;54(4):851-862. No prevalence or incidence reported. [pmid: 4193250].
McPhillips J. Understanding coeliac disease: symptoms and long-term risks. Br J Nurs. 2000;9(8):479-483. No prevalence or incidence reported. [pmid: 11143669].
Mearin M L, Biemond I, Pena A S, et al. HLA-DR phenotypes in Spanish coeliac children: their contribution to the understanding of the genetics of the disease. Gut. 1983;24(6):532-537. No prevalence or incidence reported. [pmid: 6602084]. [pmcid: 1420005].
Mearin M L, Bouquet J, Mourad N, et al. HLA-DR antigens and phenotypes in Dutch coeliac children and their families. Clin Genet. 1985;27(1):45-50. No prevalence or incidence reported. [pmid: 3872185].
Mearin M L, Koninckx C R, Biemond I, et al. Influence of genetic factors on the serum levels of antigliadin antibodies in celiac disease. J Pediatr Gastroenterol Nutr. 1984;3(3):373-377. No prevalence or incidence reported. [pmid: 6588183].
Mearin M L, Polanco I, Strober W, et al. B-cell antigens recognized by maternal antisera in gluten-sensitive enteropathy. J Clin Nutr Gastroenterol. 1986;1(1):30-36. No prevalence or incidence reported.
Meddeb-Garnaoui A, Zeliszewski D, Mougenot J F, et al. Reevaluation of the relative risk for susceptibility to celiac disease of HLA-DRB1, -DQA1, -DQB1, -DPB1, and -TAP2 alleles in a French population. Hum Immunol. 1995;43(3):190-199. No prevalence or incidence reported. [pmid: 7558936].
Mediene S, Hakem S, Bard J M, et al. Serum lipoprotein profile in Algerian patients with celiac disease. Clin Chim Acta. 1995;235(2):189-196. No prevalence or incidence reported. [pmid: 7554273].
Meeuwisse G W. Immunological consideration on breast vs. formula feeding. Klin Padiatr. 1985;197(4):322-325. No prevalence or incidence reported. [pmid: 4046489].
Mehra N K, Kaur Gurvinder, Kanga Uma et al. Immunogenetics of autoimmune diseases in Asian Indians. Ann N Y Acad Sci 2002;858333–336. No prevalence or incidence reported
Meini A, Pillan N M, Villanacci V, et al. Prevalence and diagnosis of celiac disease in IgA-deficient children. Annals of Allergy, Asthma & Immunology - Official Publication of the American College of Allergy, Asthma, & Immunology. 1996;77(4):333-336. Not a relevant screening group. [pmid: 8885812].
Meloni G F, Dessole S, Vargiu N, et al. The prevalence of coeliac disease in infertility. Hum Reprod. 1999;14(11):2759-2761. Not a relevant screening group. [pmid: 10548618].
Meloni G F, Tomasi P A, Bertoncelli A, et al. Prevalence of silent celiac disease in patients with autoimmune thyroiditis from Northern Sardinia. J Endocrinol Invest. 2001;24(5):298-302. No prevalence or incidence reported. [pmid: 11407647].
Meloni G, Dore A, Fanciulli G et al. Subclinical coeliac disease in schoolchildren from northern Sardinia. Lancet 1999;353(9146):37Not a relevant screening geography
Menendez-Corrada R. Current views on tropical sprue and a comparison to nontropical sprue. Med Clin North Am. 1968;52(6):1367-1385. No prevalence or incidence reported. [pmid: 4886058].
Messmann H. Squamous cell cancer of the oesophagus. Best Practice & Research. Clinical Gastroenterology. 2001;15(2):249-265. No prevalence or incidence reported. [pmid: 11355914].
Metcalf J. Coeliac disease and primary biliary cirrhosis: a case for mutual screening. Gut. 1998;42(1):9-10. No prevalence or incidence reported. [pmid: 9505876].
Metcalfe D D. Food hypersensitivity. J Allergy Clin Immunol. 1984;73(6):749-762. No prevalence or incidence reported. [pmid: 6609945].
Metskula K, Grunberg H, Uibo O, et al. Antigliadin antibodies and autoantibodies among 9, 12 and 15 year-old schoolchildren. Cent-Eur J Immunol. 1998;23(34):197-202. Not a relevant screening geography.
Meuli R, Pichler W J, Gaze H, et al. Genetic difference in HLA-DR phenotypes between coeliac disease and transitory gluten intolerance. Arch Dis Child. 1995;72(1):29-32. No prevalence or incidence reported. [pmid: 7717732].
Meyer D, Stavropolous S, Diamond B, et al. Osteoporosis in a north american adult population with celiac disease. Am J Gastroenterol. 2001;96(1):112-119. No prevalence or incidence reported. [pmid: 11197239].
Meyer L J, Zone J J. Familial incidence of dermatitis herpetiformis. J Am Acad Dermatol. 1987;17(4):643-647. No prevalence or incidence reported. [pmid: 3312315].
Michaelsen K F, Weile B, Larsen P, et al. Does the low intake of wheat in Danish infants cause the low incidence rate of coeliac disease?. Acta Paediatr. 1993;82(67):605-606. No prevalence or incidence reported. [pmid: 8339001].
Michaelsson G, Gerden B, Hagforsen E, et al. Psoriasis patients with antibodies to gliadin can be improved by a gluten-free diet. Br J Dermatol. 2000;142(1):44-51. No prevalence or incidence reported. [pmid: 10651693].
Michaelsson G, Gerden B, Ottosson M, et al. Patients with psoriasis often have increased serum levels of IgA antibodies to gliadin. Br J Dermatol. 1993;129(6):667-673. No prevalence or incidence reported. [pmid: 8286249].
Michaelsson G, Kraaz W, Gerden B, et al. Increased lymphocyte infiltration in duodenal mucosa from patients with psoriasis and serum IgA antibodies to gliadin. Br J Dermatol. 1995;133(6):896-904. No prevalence or incidence reported. [pmid: 8547041].
Michalski J P, McCombs C C, Arai T, et al. HLA-DR, DQ genotypes of celiac disease patients and healthy subjects from the West of Ireland. Tissue Antigens. 1996;47(2):127-133. No prevalence or incidence reported. [pmid: 8851726].
Midhagen G, Jarnerot G, Kraaz W. Adult coeliac disease within a defined geographic area in Sweden. A study of prevalence and associated diseases. Scand J Gastroenterol. 1988;23(8):1000-1004. [pmid: 3201123].
Midhagen G, Jarnerot G, Kraaz W. Adult coeliac disease within a defined geographic area in Sweden. A study of prevalence and associated diseases. Scand J Gastroenterol. 1988;23(8):1000-1004. Serology screen <1990. [pmid: 3201123].
Mignot E, Kimura A, Abbal M, et al. DQCAR microsatellite polymorphisms in three selected HLA class II-associated diseases. Tissue Antigens. 1995;46(4):299-304. No prevalence or incidence reported. [pmid: 8560448].
Miller Karen K. Mechanisms by which nutritional disorders cause reduced bone mass in adults. J Womens Health (Larchmt). 2003;12(2):145-150. No prevalence or incidence reported. [pmid: 12737712].
Miller M L. Clinical aspects of juvenile rheumatoid arthritis. Curr Opin Rheumatol. 1997;9(5):423-427. No prevalence or incidence reported. [pmid: 9375282].
Mitchell R M S, Robinson T J. Monitoring dietary compliance in coeliac disease using red cell distribution width. Int J Clin Pract. 2002;56(4):249-250. No prevalence or incidence reported. [pmid: 12074205].
Mitt K, Uibo O. Low cereal intake in Estonian infants: the possible explanation for the low frequency of coeliac disease in Estonia. Eur J Clin Nutr. 1998;52(2):85-88. No prevalence or incidence reported. [pmid: 9505150].
Mittal K K. Immunobiology of the human major histocompatibility complex: association of HLA antigens with disease. Acta Anthropogenet. 1984;8(34):245-268. No prevalence or incidence reported. [pmid: 6400312].
Mittal S K. Chronic diarrhea in tropics. Indian J Pediatr. 1999;66(1 Suppl):S4-15. No prevalence or incidence reported. [pmid: 11132468].
Moayyedi P, O'Mahony S, Jackson P, et al. Small intestine in lymphocytic and collagenous colitis: mucosal morphology, permeability, and secretory immunity to gliadin. J Clin Pathol. 1997;50(6):527-529. No prevalence or incidence reported. [pmid: 9378824]. [pmcid: 500002].
Mody G M, Cassim B. Rheumatologic manifestations of gastrointestinal disorders. Curr Opin Rheumatol. 1998;10(1):67-72. No prevalence or incidence reported. [pmid: 9448992].
Mohindra S, Yachha S K, Srivastava A, et al. Coeliac disease in Indian children: assessment of clinical, nutritional and pathologic characteristics. J Health Popul Nutr. 2001;19(3):204-208. Not a relevant screening geography. [pmid: 11761775].
Mohn A, Cerruto M, Lafusco D, et al. Celiac disease in children and adolescents with type I diabetes: importance of hypoglycemia. J Pediatr Gastroenterol Nutr. 2001;32(1):37-40. No prevalence or incidence reported. [pmid: 11176322].
Mokhallalaty M, Debek A, Naja Z, et al. Celiac disease at Makassed General Hospital (8 years of experience). Rev Med Liban. 2002;14(23):49-53. No prevalence or incidence reported.
Molteni N, Bardella M T, Bianchi P A. Obstetric and gynecological problems in women with untreated celiac sprue. J Clin Gastroenterol. 1990;12(1):37-39. No prevalence or incidence reported. [pmid: 2303686].
Molteni N, Bardella M T, Vezzoli G, et al. Intestinal calcium absorption as shown by stable strontium test in celiac disease before and after gluten-free diet. Am J Gastroenterol. 1995;90(11):2025-2028. No prevalence or incidence reported. [pmid: 7485015].
Molteni N, Caraceni M P, Bardella M T, et al. Bone mineral density in adult celiac patients and the effect of gluten-free diet from childhood. Am J Gastroenterol. 1990;85(1):51-53. No prevalence or incidence reported. [pmid: 2296964].
Moneo I, Alday E, Gonzalez-Munoz M, et al. alpha-amylase hypersensitivity in non-exposed millers. Occup Med. 1994;44(2):91-94. No prevalence or incidence reported.
Moneret-Vautrin D A, Kanny G, Morisset M, et al. The food anaphylaxis Vigilance Network in France. Allergy Clin Immunol Int. 2003;15(4):155-159. No prevalence or incidence reported.
Monetini L, Cavallo M G, Manfrini S, et al. Antibodies to bovine beta-casein in diabetes and other autoimmune diseases. Hormone and Metabolic Research.Hormon- Und Stoffwechselforschung. Hormones Et Metabolisme. 2002;34(8):455-459. No prevalence or incidence reported. [pmid: 12198602].
Montalto G, Carroccio A, Soresi M, et al. Chronic pancreatitis in Sicily. Preliminary reports. Ital J Gastroenterol. 1990;22(1):33-35. No prevalence or incidence reported. [pmid: 2131926].
Monteiro E, Menezes M L, Magalhaes Ramalho P. Anti-reticulin antibodies: a diagnostic and monitoring test for childhood coeliac disease. Scand J Gastroenterol. 1986;21(8):955-957. No prevalence or incidence reported. [pmid: 3535013].
Montgomery R D, Atiyeh M, Scales W R, et al. Intestinal absorption in Saudi Arabia: an evaluation of the one hour blood xylose test. Trans R Soc Trop Med Hyg. 1982;76(1):25-28. No prevalence or incidence reported. [pmid: 7080153].
Montgomery R D, Shearer A C I. The cell population of the upper jejunal mucosa in tropical sprue and postinfective malabsorption. Gut. 1974;15(5):387-391. No prevalence or incidence reported. [pmid: 18668848].
Moodie S J, Norman P J, King A L, et al. Analysis of candidate genes on chromosome 19 in coeliac disease: an association study of the KIR and LILR gene clusters. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 2002;29(4):287-291. No prevalence or incidence reported. [pmid: 12121272].
Moodie S, Ciclitira P. Coeliac disease: Genetic factors and antigen presentation: MALADIE CoeLIAQUE: FACTEURS GENETIQUES ET PRESENTATION DES ANTIGENES. Acta Endoscopica. 2001;31(3):255-264. No prevalence or incidence reported.
Mooradian A D, Morley J E, Levine A S, et al. Abnormal intestinal permeability to sugars in diabetes mellitus. Diabetologia. 1986;29(4):221-224. No prevalence or incidence reported. [pmid: 3519337].
Moore R H, Hitman G A, Medcraft J, et al. HLA-DP region gene polymorphism in primary IgA nephropathy: No association. Nephrol Dial Transplant. 1992;7(3):200-204. No prevalence or incidence reported. [pmid: 1314989].
Mora Barbara, Bonamico Margherita, Indovina Paola, et al. CTLA-4 +49 A/G dimorphism in Italian patients with celiac disease. Hum Immunol. 2003;64(2):297-301. No prevalence or incidence reported. [pmid: 12559633].
Mora S, Barera G, Beccio S, et al. A prospective, longitudinal study of the long-term effect of treatment on bone density in children with celiac disease. Eur J Pediatr. 2001;139(4):516-521. No prevalence or incidence reported.
Mora S, Barera G, Beccio S, et al. Bone density and bone metabolism are normal after long-term gluten-free diet in young celiac patients. Am J Gastroenterol. 1999;94(2):398-403. No prevalence or incidence reported. [pmid: 10022636].
Mora S, Barera G, Ricotti A, et al. Reversal of low bone density with a gluten-free diet in children and adolescents with celiac disease. Am J Clin Nutr. 1998;67(3):477-481. No prevalence or incidence reported. [pmid: 9497193].
Mora S, Weber G, Barera G, et al. Effect of gluten-free diet on bone mineral content in growing patients with celiac disease. Am J Clin Nutr. 1993;57(2):224-228. No prevalence or incidence reported. [pmid: 8424392].
Moran C E, Sosa E G, Martinez S M, et al. Bone mineral density in patients with pancreatic insufficiency and steatorrhea. Am J Gastroenterol. 1997;92(5):867-871. No prevalence or incidence reported. [pmid: 9149203].
Morelli M S, Zucker S D, Radford-smith G, et al. A role for the appendix in inflammatory bowel disease? Cut it out. Gastroenterology. 2003;125(4):1270-1272. No prevalence or incidence reported. [pmid: 15108715].
Morellini M, Trabace S, Mazzilli M C, et al. A study of HLA class II antigens in an Italian paediatric population with coeliac disease. Dis Markers. 1988;6(1):23-28. No prevalence or incidence reported. [pmid: 3396269].
Morris M A, Yiannakou J Y, King A L, et al. Coeliac disease and Down syndrome: associations not due to genetic linkage on chromosome 21. Scand J Gastroenterol. 2000;35(2):177-180. No prevalence or incidence reported. [pmid: 10720116].
Morrow-Brown H. A holistic view of allergic disease. Human Nutrition. Applied Nutrition. 1984;38(6):421-434. No prevalence or incidence reported. [pmid: 6526688].
Mortimer P E, Stewart J S, Norman A P, et al. Follow-up study of coeliac disease. Br Med J. 1968;3(609):7-9. No prevalence or incidence reported. [pmid: 5661931]. [pmcid: 1989483].
Morton N E. An exact linkage test for multiple case families. Hum Hered. 1983;33(4):244-249. No prevalence or incidence reported. [pmid: 6885087].
Moynahan E J. Skin disease and the gut. Br Med J. 1970;4(734):559-560. No prevalence or incidence reported. [pmid: 5483338].
Muench R, Ammann R. Fecal immunoreactive lipase: a new tubeless pancreatic function test. Scand J Gastroenterol. 1992;27(4):289-294. No prevalence or incidence reported. [pmid: 1589707].
Muers M F, Faux J A, Ting A, et al. HLA-A, B, C and HLA-DR antigens in extrinsic allergic alveolitis (budgerigar fancier's lung disease). Clin Allergy. 1982;12(1):47-53. No prevalence or incidence reported. [pmid: 7067067].
Mugica F, Aranzadi M J, Recasens M, et al. Adult celiac disease and hypertransaminasemia. Revista Espanola De Enfermedades Digestivas - Organo Oficial De La Sociedad Espanola De Patologia Digestiva. 2000;92(2):78-85. No prevalence or incidence reported. [pmid: 10757865].
Mugica F, Castiella A, Otazua P, et al. Prevalence of coeliac disease in unexplained chronic hypertransaminasemia. Revista Espanola De Enfermedades Digestivas - Organo Oficial De La Sociedad Espanola De Patologia Digestiva. 2001;93(11):707-714. No prevalence or incidence reported. [pmid: 11995370].
Mulder C J J, Tytgat G N J, Groenland F, et al. Combined coeliac disease and thyroid disease, a study of 17 cases. J Clin Nutr Gastroenterol. 1988;3(3):89-92. No prevalence or incidence reported.
Mulder C J. Do we have to screen the general population for coeliac disease instead of only patients with so-called associated diseases?. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2000;32(9):780-781. No prevalence or incidence reported. [pmid: 11215558].
Mulder Chris J J, Hadithi Mohammed M, Rostami Kamran, et al. Coeliac disease--has the time come for routine mass screening? In 2002--2010--2020?. Rom J Gastroenterol. 2002;11(3):179-182. No prevalence or incidence reported. [pmid: 12368936].
Murray I A, Clenton S, McGeorge B A, et al. Retrospective audit of the value of the pancreolauryl test in a district general hospital. Postgrad Med J. 2003;79(934):471-473. No prevalence or incidence reported. [pmid: 12954962].
Murray I A, Coupland K, Smith J A, et al. Intestinal trehalase activity in a UK population: establishing a normal range and the effect of disease. Br J Nutr. 2000;83(3):241-245. No prevalence or incidence reported. [pmid: 10884712].
Murray Iain A, Daniels Ian, Coupland Kathryn, et al. Increased activity and expression of iNOS in human duodenal enterocytes from patients with celiac disease. American Journal of Physiology. Gastrointestinal and Liver Physiology. 2002;283(2):G319-G326. No prevalence or incidence reported. [pmid: 12121878].
Murray J A, Herlein J, Mitros F, et al. Serologic testing for celiac disease in the United States: Results of a multilaboratory comparison study. Clin Diagn Lab Immunol. 2000;7(4):584-587. No prevalence or incidence reported. [pmid: 10882656]. [pmcid: 95918].
Murray J A, Van Dyke C, Plevak M F, et al. Trends in the identification and clinical features of celiac disease in a North American community, 1950-2001. Clin Gastroenterol Hepatol. 2003;1(1):19-27. No prevalence or incidence reported. [pmid: 15017513].
Murray J A. Serodiagnosis of celiac disease. Clin Lab Med. 1997;17(3):445-464. No prevalence or incidence reported. [pmid: 9316768].
Murray J A. The widening spectrum of celiac disease. Am J Clin Nutr. 1999;69(3):354-365. No prevalence or incidence reported. [pmid: 10195608].
Mustalahti K, Holopainen P, Karell K, et al. Genetic dissection between silent and clinically diagnosed symptomatic forms of coeliac disease in multiplex families. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(12):842-845. No prevalence or incidence reported. [pmid: 12643291].
Mustalahti Kirsi, Lohiniemi Susanna, Collin Pekka, et al. Gluten-free diet and quality of life in patients with screen-detected celiac disease. Effective Clinical Practice - Ecp. 2002;5(3):105-113. No prevalence or incidence reported. [pmid: 12088289].
Muzzo S, Burrows R, Burgueno M, et al. Effect of calcium and vitamin D supplementation on bone mineral density of celiac children. Nutr Res. 2000;20(9):1241-1247. No prevalence or incidence reported.
Myhre A G, Aarsetoy H, Undlien D E, et al. High frequency of coeliac disease among patients with autoimmune adrenocortical failure. Scand J Gastroenterol. 2003;38(5):511-515. No prevalence or incidence reported. [pmid: 12795461].
Mylotte M, Egan-Mitchell B, Fottrell P F, et al. Family studies in coeliac disease. Q J Med. 1974;43(171):359-369. Serology screen <1990. [pmid: 4421975].
Mylotte M, Egan-Mitchell B, Fottrell P F, et al. Fingerprints in patients with coeliac disease and their relatives. Br Med J. 1972;4(833):144-146. No prevalence or incidence reported. [pmid: 5078446]. [pmcid: 1786410].
Mylotte M, Egan-Mitchell B, McCarthy C F, et al. Coeliac disease in the West of Ireland. Br Med J. 1973;3(5878):498-499. No prevalence or incidence reported. [pmid: 4726162].
Mylotte M, Egan-Mitchell B, McCarthy C F, et al. Incidence of coeliac disease in the West of Ireland. Br Med J. 1973;1(5855):703-705. Serology screen <1990. [pmid: 4726162]. [pmcid: 1588876].
Myrelid A, Gustafsson J, Ollars B, et al. Growth charts for Down Syndrome from birth to 18 years of age. Arch Dis Child. 2002;87(2):97-103. No prevalence or incidence reported. [pmid: 12138052].
Nakamura T, Takeuchi T. Pancreatic steatorrhea, malabsorption, and nutrition biochemistry: a comparison of Japanese, European, and American patients with chronic pancreatitis. Pancreas. 1997;14(4):323-333. No prevalence or incidence reported. [pmid: 9163777].
Nakamura T, Tando Y, Terada A, et al. Can pancreatic steatorrhea be diagnosed without chemical analysis?. International Journal of Pancreatology - Official Journal of the International Association of Pancreatology. 1997;22(2):121-125. No prevalence or incidence reported. [pmid: 9387033].
Nakamura T, Tando Y, Yamada N, et al. Study on pancreatic insufficiency (chronic pancreatitis) and steatorrhea in Japanese patients with low fat intake. Digestion. 1999;60(Suppl 1):93-96. No prevalence or incidence reported. [pmid: 10026440].
Nakshabendi I M, Downie S, Russell R I, et al. Increased rates of duodenal mucosal protein synthesis in vivo in patients with untreated coelia disease. Gut. 1996;39(2):176-179. No prevalence or incidence reported. [pmid: 8991854]. [pmcid: 1383294].
Naluai A T, Nilsson S, Gudjonsdottir A H, et al. Genome-wide linkage analysis of Scandinavian affected sib-pairs supports presence of susceptibility loci for celiac disease on chromosomes 5 and 11. European Journal of Human Genetics - Ejhg. 2001;9(12):938-944. No prevalence or incidence reported. [pmid: 11840196].
Naluai A T, Nilsson S, Samuelsson L, et al. The CTLA4/CD28 gene region on chromosome 2q33 confers susceptibility to celiac disease in a way possibly distinct from that of type 1 diabetes and other chronic inflammatory disorders. Tissue Antigens. 2000;56(4):350-355. No prevalence or incidence reported. [pmid: 11098935].
Nash Samantha. Does exclusive breast-feeding reduce the risk of coeliac disease in children?. Br J Community Nurs. 2003;8(3):127-132. No prevalence or incidence reported. [pmid: 12682607].
Naveh Y, Lightman A, Zinder O. A prospective study of serum zinc concentration in children with celiac disease. Eur J Pediatr. 1983;102(5):734-736. No prevalence or incidence reported.
Nazer H. Gastroenterological problems in childhood in Jordan. Ann Trop Paediatr. 1982;2(2):69-72. No prevalence or incidence reported. [pmid: 6185081].
Neale G. Generalised disorders of bone associated with disease of the gastro-intestinal tract. Ir J Med Sci. 1974;0(Suppl):57-63. No prevalence or incidence reported. [pmid: 4604501].
Nelsen D A. Gluten-sensitive enteropathy (celiac disease): More common than you think. Am Fam Phys. 2002;66(12):2259-22662269. No prevalence or incidence reported.
Nelsen David A. Gluten-sensitive enteropathy (celiac disease): more common than you think. Am Fam Physician. 2002;66(12):2259-2266. No prevalence or incidence reported. [pmid: 12507163].
Nelson R, McNeish A S, Anderson C M. Coeliac disease in children of Asian immigrants. Lancet. 1973;1(7799):348-350. No prevalence or incidence reported. [pmid: 4121938].
Nepom G T, Erlich H. MHC class-II molecules and autoimmunity. Annu Rev Immunol 1991;9493–525. No prevalence or incidence reported
Nepom G T. MHC genes in HLA-associated disease. Curr Opin Immunol. 1990;2(4):588-592. No prevalence or incidence reported. [pmid: 2700901].
Neuberger J. PBC and the gut: the villi atrophy, the plot thickens. Gut. 1999;44(5):594-595. No prevalence or incidence reported. [pmid: 10485854]. [pmcid: 1727492].
Neuhausen Susan L, Feolo Mike, Camp Nicola J, et al. Genome-wide linkage analysis for celiac disease in North American families. Am J Med Genet. 2002;111(1):1-9. No prevalence or incidence reported. [pmid: 12124726].
Neuhausen Susan L, Weizman Zvi, Camp Nicola J, et al. HLA DQA1-DQB1 genotypes in Bedouin families with celiac disease. Hum Immunol. 2002;63(6):502-507. No prevalence or incidence reported. [pmid: 12039527].
Nicolas M E O, Krause P K, Gibson L E, et al. Dermatitis herpetiformis. Int J Dermatol. 2003;42(8):588-600. No prevalence or incidence reported. [pmid: 12890100].
Nielsen I M, Ornvold K, Jacobsen B B, et al. Fatal familial cholestatic syndrome in Greenland Eskimo children. Acta Paediatr Scand. 1986;75(6):1010-1016. No prevalence or incidence reported. [pmid: 3564958].
Nielsen O H, Jacobsen O, Pedersen E R, et al. Non-tropical sprue. Malignant diseases and mortality rate. Scand J Gastroenterol. 1985;20(1):13-18. No prevalence or incidence reported. [pmid: 3992161].
Nieminen U, Kahri A, Savilahti E, et al. Duodenal disaccharidase activities in the follow-up of villous atrophy in coeliac disease. Scand J Gastroenterol. 2001;36(5):507-510. No prevalence or incidence reported. [pmid: 11346204].
Nieto A, Blanco Quiros A, Arranz E, et al. Study of HLA-DQA1 alleles in celiac children. Journal of Investigational Allergology & Clinical Immunology - Official Organ of the International Association of Asthmology (Interasma) and Sociedad Latinoamericana De Alergia E Inmunologia. 1995;5(4):209-215. No prevalence or incidence reported. [pmid: 8705011].
Niggemann B, Reibel S, Roehr C C, et al. Predictors of positive food challenge outcome in non-IgE-mediated reactions to food in children with atopic dermatitis. J Allergy Clin Immunol. 2001;108(6):1053-1058. No prevalence or incidence reported. [pmid: 11742288].
Niggemann B, Sielaff B, Beyer K, et al. Outcome of double-blind, placebo-controlled food challenge tests in 107 children with atopic dermatitis. Clinical and Experimental Allergy - Journal of the British Society for Allergy and Clinical Immunology. 1999;29(1):91-96. No prevalence or incidence reported. [pmid: 10051707].
Nilssen D E, Brandtzaeg P, Froland S S, et al. Subclass composition and J-chain expression of the ‘compensatory’ gastrointestinal IgG cell population in selective IgA deficiency. Clin Exp Immunol. 1992;87(2):237-245. No prevalence or incidence reported. [pmid: 1735187]. [pmcid: 1554248].
Nilsson A. Lactose malabsorption and lactose intolerance in adults - A cause of irritable bowel syndrome?. Scand J Nutr Naringsforsk. 2001;45(4):175-176. No prevalence or incidence reported.
Niveloni S, Dezi R, Pedreira S, et al. Gluten sensitivity in patients with primary biliary cirrhosis. Am J Gastroenterol. 1998;93(3):404-408. No prevalence or incidence reported. [pmid: 9580141].
Niveloni S, Fiorini A, Dezi R, et al. Usefulness of videoduodenoscopy and vital dye staining as indicators of mucosal atrophy of celiac disease: assessment of interobserver agreement. Gastroenterol Int. 1998;47(3):223-229. No prevalence or incidence reported.
Niveloni S, Pedreira S, Sugai E, et al. The natural history of gluten sensitivity: report of two new celiac disease patients resulting from a long-term follow-up of nonatrophic, first-degree relatives. Am J Gastroenterol. 2000;95(2):463-468. No prevalence or incidence reported. [pmid: 10685751].
Niven M J, Caffrey C, Moore R H, et al. T-cell receptor beta-subunit gene polymorphism and autoimmune disease. Hum Immunol. 1990;27(4):360-367. No prevalence or incidence reported. [pmid: 1969400].
Norgard B, Fonager K, Sorensen H T, et al. Birth outcomes of women with celiac disease: a nationwide historical cohort study. Am J Gastroenterol. 1999;94(9):2435-2440. No prevalence or incidence reported. [pmid: 10484005].
Norris T S. Three familial cases of adult idiopathic steatorrhoea. Proc R Soc Med. 1966;59(10):1005-1006. No prevalence or incidence reported. [pmid: 5955757]. [pmcid: 1901038].
Nosari I, Casati A, Mora C, et al. The use of IgA-antiendomysial antibody test for screening coeliac disease in insulin-dependent diabetes mellitus. Diabetes Nutr Metab Clin Exp. 1996;9(5):267-272. No prevalence or incidence reported.
Not T, Citta A, Lucchesi A, et al. Anti-endomysium antibody on human umbilical cord vein tissue: an inexpensive and sensitive diagnostic tool for the screening of coeliac disease. Eur J Pediatr. 1997;156(8):616-618. No prevalence or incidence reported. [pmid: 9266192].
Not T, Ventura A, Peticarari S, et al. A new, rapid, noninvasive screening test for celiac disease. Eur J Pediatr. 1993;123(3):425-427. No prevalence or incidence reported.
Not Tarcisio, Faleschini Elena, Tommasini Alberto, et al. Celiac disease in patients with sporadic and inherited cardiomyopathies and in their relatives. Eur Heart J. 2003;24(15):1455-1461. No prevalence or incidence reported. [pmid: 12909075].
Nousia-Arvanitakis S, Karagiozoglou-Lamboudes T, Aggouridaki C, et al. Influence of jejunal morphology changes on exocrine pancreatic function in celiac disease. J Pediatr Gastroenterol Nutr. 1999;29(1):81-85. No prevalence or incidence reported. [pmid: 10400109].
Novacek G, Miehsler W, Wrba F, et al. Prevalence and clinical importance of hypertransaminasaemia in coeliac disease. Eur J Gastroenterol Hepatol. 1999;11(3):283-288. No prevalence or incidence reported. [pmid: 10333201].
Novembre E, Cianferoni A, Bernardini R, et al. Epidemiology of insect venom sensitivity in children and its correlation to clinical and atopic features. Clin Exp Allergy. 1998;28(7):834-838. No prevalence or incidence reported. [pmid: 9720817].
Nowak-Wegrzyn A, Conover-Walker M K, Wood R A. Food-allergic reactions in schools and preschools. Arch Pediatr Adolesc Med. 2001;155(7):790-795. No prevalence or incidence reported. [pmid: 11434845].
Nowowiejska B, Kaczmarski M, Dabrowska E J. A long-term study in children with a recognized gluten intolerance. Rocz Akad Med Bialymst. 1995;40(3):580-587. No prevalence or incidence reported. [pmid: 8775310].
O'Boyle C J, Kerin M J, Feeley K, et al. Primary small intestinal tumours: increased incidence of lymphoma and improved survival. Ann R Coll Surg Engl. 1998;80(5):332-334. No prevalence or incidence reported. [pmid: 9849332].
O'Connor T M, Cronin C C, Loane J F, et al. Type 1 diabetes mellitus, coeliac disease, and lymphoma: a report of four cases. Diabetic Medicine - a Journal of the British Diabetic Association. 1999;16(7):614-617. No prevalence or incidence reported. [pmid: 10445840].
Oderda Giuseppina, Rapa Anna, Zavallone Annalisa, et al. Thyroid autoimmunity in childhood celiac disease. J Pediatr Gastroenterol Nutr. 2002;35(5):704-705. No prevalence or incidence reported. [pmid: 12454591].
Odetti P, Valentini S, Aragno I, et al. Oxidative stress in subjects affected by celiac disease. Free Radic Res. 1998;29(1):17-24. No prevalence or incidence reported. [pmid: 9733018].
O'Farrelly C, Graeme-Cook F, Hourihane D O, et al. Histological changes associated with wheat protein antibodies in the absence of villous atrophy. J Clin Pathol. 1987;40(10):1228-1230. No prevalence or incidence reported. [pmid: 3680547]. [pmcid: 1141200].
O'Farrelly C. Is villous atrophy always and only the result of gluten sensitive disease of the intestine?. Eur J Gastroenterol Hepatol. 2000;12(6):605-608. No prevalence or incidence reported. [pmid: 10912475].
Ogborn A D. Pregnancy in patients with coeliac disease. Br J Obstet Gynaecol. 1975;82(4):293-296. No prevalence or incidence reported. [pmid: 1125150].
O'Gorman P, Bennett D, Kavanagh E, et al. MALTectomy (appendectomy/tonsillectomy) does not influence the occurrence or mode of presentation of adult celiac disease. Am J Gastroenterol. 1996;91(4):723-725. No prevalence or incidence reported. [pmid: 8677937].
O'Grady J G, Stevens F M, Harding B, et al. Hyposplenism and gluten-sensitive enteropathy. Natural history, incidence, and relationship to diet and small bowel morphology. Gastroenterology. 1984;87(6):1326-1331. No prevalence or incidence reported. [pmid: 6489698].
O'Grady J G, Stevens F M, McCarthy C F. Genetic influences on splenic function in coeliac disease. Gut. 1985;26(10):1004-1007. No prevalence or incidence reported. [pmid: 3876972]. [pmcid: 1432950].
O'Keefe S J, O'Keefe E A, Burke E, et al. Milk-induced malabsorption in malnourished African patients. Am J Clin Nutr. 1991;54(1):130-135. No prevalence or incidence reported. [pmid: 1905476].
Olden Kevin W. Diagnosis of irritable bowel syndrome. Gastroenterology. 2002;122(6):1701-1714. No prevalence or incidence reported. [pmid: 12454866].
Olds G, McLoughlin R, O'Morian C, et al. Celiac disease for the endoscopist. Gastrointest Endosc. 2002;56(3):407-415. No prevalence or incidence reported. [pmid: 12196781].
O'Leary C, Walsh C H, Wieneke P, et al. Coeliac disease and autoimmune Addison's disease: a clinical pitfall. Qjm - Monthly Journal of the Association of Physicians. 2002;95(2):79-82. No prevalence or incidence reported. [pmid: 11861954].
O'Leary Clare, Quigley Eamonn M M. Small bowel bacterial overgrowth, celiac disease, and IBS: what are the real associations?. Am J Gastroenterol. 2003;98(4):720-722. No prevalence or incidence reported. [pmid: 12738446].
O'Leary Clare, Wieneke Peter, Buckley Sarah, et al. Celiac disease and irritable bowel-type symptoms. Am J Gastroenterol. 2002;97(6):1463-1467. No prevalence or incidence reported. [pmid: 12094866].
Olsson R, Kagevi I, Rydberg L. On the concurrence of primary biliary cirrhosis and intestinal villous atrophy. Scand J Gastroenterol. 1982;17(5):625-628. No prevalence or incidence reported. [pmid: 6983714].
Olsson R, Lindberg J, Weiland O, et al. Chronic active hepatitis in Sweden. The etiologic spectrum, clinical presentation, and laboratory profile. Scand J Gastroenterol. 1988;23(4):463-470. No prevalence or incidence reported. [pmid: 3381068].
O'Reilly D, Murphy J, McLaughlin J, et al. The prevalence of coeliac disease and cystic fibrosis in Ireland, Scotland, England and Wales. Int J Epidemiol. 1974;3(3):247-251. Serology screen <1990. [pmid: 4416432].
Orgad S, Avigad S, Jonas A, et al. Immunogenetics of childhood celiac disease: the association with HDA DR3 and DR7 in unrelated patients with multiply affected families. Isr J Med Sci. 1981;17(11):1041-1044. No prevalence or incidence reported. [pmid: 6797985].
Ortolani C, Ispano M, Scibilia J, et al. Introducing chemists to food allergy. Allergy. 2001;56(Suppl 67):5-8. No prevalence or incidence reported. [pmid: 11297997].
Ots M, Uibo O, Metskula K, et al. IgA-antigliadin antibodies in patients with IgA nephropathy: the secondary phenomenon?. American Journal of Nephrology. 1999;19(4):453-458. Not sensitivity or specificity of an identified test. [pmid: 10460933].
Ott D J. Celiac disease: biopsy or enteroclysis better for evaluating response to a gluten-free diet?. Am J Gastroenterol. 1997;92(4):715-716. No prevalence or incidence reported. [pmid: 9382045].
Oxentenko A S, Murray J A. Celiac disease and dermatitis herpetiformis: The spectrum of gluten-sensitive enteropathy. Int J Dermatol. 2003;42(8):585-587. No prevalence or incidence reported. [pmid: 12890099].
Ozgenc F, Aksu G, Aydogdu S, et al. Association between anti-endomysial antibody and total intestinal villous atrophy in children with coeliac disease. J Postgrad Med. 2003;49(1):21-24. No prevalence or incidence reported. [pmid: 12865566].
Ozkan T, Ozeke T, Meral A. Gliadin-specific IgA antibodies in breast milk. J Int Med Res. 2000;28(5):234-240. No prevalence or incidence reported. [pmid: 11092234].
Padmanabhan Vijayalakshmi, Callas Peter W, Li Shuan C, et al. Histopathological features of the terminal ileum in lymphocytic and collagenous colitis: a study of 32 cases and review of literature. Modern Pathology - an Official Journal of the United States and Canadian Academy of Pathology, Inc. 2003;16(2):115-119. No prevalence or incidence reported. [pmid: 12591963].
Paerregaard A, Vilien M, Krasilnikoff P A, et al. Supposed coeliac disease during childhood and its presentation 14–38 years later. Scand J Gastroenterol. 1988;23(1):65-70. No prevalence or incidence reported. [pmid: 3344399].
Paimela L, Kurki P, Leirisalo-Repo M, et al. Gliadin immune reactivity in patients with rheumatoid arthritis. Clin Exp Rheumatol. 1995;13(5):603-607. No prevalence or incidence reported. [pmid: 8575138].
Palavecino E A, Mota A H, Awad J, et al. HLA and celiac disease in Argentina: involvement of the DQ subregion. Dis Markers. 1990;8(1):5-10. No prevalence or incidence reported. [pmid: 2311351].
Papadopoulos A J, Schwartz R A, Krysicka Janniger C. Alopecia areata: Emerging concepts. Acta Dermatovenerol Alp Panonica Adriat. 2000;9(3):83-90. No prevalence or incidence reported.
Papadopoulos K I, Hornblad Y, Hallengren B. The occurrence of polyglandular autoimmune syndrome type III associated with coeliac disease in patients with sarcoidosis. J Intern Med. 1994;236(6):661-663. No prevalence or incidence reported. [pmid: 7989901].
Papadopoulos K I, Sjoberg K, Lindgren S, et al. Evidence of gastrointestinal immune reactivity in patients with sarcoidosis. J Intern Med. 1999;245(5):525-531. No prevalence or incidence reported. [pmid: 10363754].
Papadopoulou A, Lloyd D R, Williams M D, et al. Gastrointestinal and nutritional sequelae of bone marrow transplantation. Arch Dis Child. 1996;75(3):208-213. No prevalence or incidence reported. [pmid: 8976659].
Papo M, Quer J C, Pastor R M, et al. Antineutrophil cytoplasmic antibodies in relatives of patients with inflammatory bowel disease. Am J Gastroenterol. 1996;91(8):1512-1515. No prevalence or incidence reported. [pmid: 8759652].
Pare P, Douville P, Caron D, et al. Adult celiac sprue: changes in the pattern of clinical recognition. J Clin Gastroenterol. 1988;10(4):395-400. No prevalence or incidence reported. [pmid: 3418086].
Parke A L. Gastrointestinal disorders and rheumatic diseases. Curr Opin Rheumatol. 1993;5(1):79-84. No prevalence or incidence reported. [pmid: 8435293].
Parnell N D, Ciclitira P J. Review article: coeliac disease and its management. Aliment Pharmacol Ther. 1999;13(1):1-13. No prevalence or incidence reported. [pmid: 10383530].
Parnell N, Ciclitira P J. Celiac disease. Curr Opin Gastroenterol. 1999;15(2):120-124. No prevalence or incidence reported. [pmid: 17023931].
Parry Sally D, Welfare Mark R, Cobden Irving, et al. Push enteroscopy in a UK district general hospital: experience of 51 cases over 2 years. Eur J Gastroenterol Hepatol. 2002;14(3):305-309. No prevalence or incidence reported. [pmid: 11953697].
Partanen J, Milner C, Campbell R D, et al. HLA-linked heat-shock protein 70 (HSP70-2) gene polymorphism and celiac disease. Tissue Antigens. 1993;41(1):15-19. No prevalence or incidence reported. [pmid: 8096093].
Partanen J. The HLA-DRB4 gene does not explain genetic susceptibility in HLA-DQ2-negative celiac disease. Immunogenetics. 2000;51(3):249-250. No prevalence or incidence reported. [pmid: 10752637].
Passarge E, Valentine-Thon E. Everything the pediatrician ever wanted to know about HLA but was afraid to ask. Eur J Pediatr. 1980;133(2):93-100. No prevalence or incidence reported. [pmid: 6988220].
Pasternack A, Collin P, Mustonen J, et al. Glomerular IgA deposits in patients with celiac disease. Clin Nephrol. 1990;34(2):56-60. No prevalence or incidence reported. [pmid: 2225554].
Patel A H, Loftus E V, Murray J A, et al. Cigarette smoking and celiac sprue: a case-control study. Am J Gastroenterol. 2001;96(8):2388-2391. No prevalence or incidence reported. [pmid: 11513179].
Patel R S, Johlin F C, Murray J A. Celiac disease and recurrent pancreatitis. Gastroenterol Int. 1999;50(6):823-827. No prevalence or incidence reported.
Patey-Mariaud de, Serre Cellier C, Jabri B, et al. Distinction between coeliac disease and refractory sprue: a simple immunohistochemical method. Histopathology. 2000;37(1):70-77. No prevalence or incidence reported. [pmid: 10931221].
Patney N L, Srivastava V K, Wahal p k, et al. A study of fat malabsorption and jejunal muscosal biopsy in diabetic neuropathy: a preliminary report. J Assoc Physicians India. 1973;21(9):777-785. No prevalence or incidence reported. [pmid: 4794854].
Patterson R N, Johnston S D. Iron deficiency anaemia: are the British Society of Gastroenterology guidelines being adhered to?. Postgrad Med J. 2003;79(930):226-228. No prevalence or incidence reported. [pmid: 12743344].
Patwari A K, Anand V K, Kapur Gaurav, et al. Clinical and nutritional profile of children with celiac disease. Indian Pediatr. 2003;40(4):337-342. No prevalence or incidence reported. [pmid: 12736407].
Patwari A K. Diarrhoea and malnutrition interaction. Indian J Pediatr. 1999;66(1 Suppl):S124-S134. No prevalence or incidence reported. [pmid: 11132472].
Pearce C B, Sinclair D, Duncan H D, et al. Use of the anti-endomysial antibody test to diagnose coeliac disease in clinical practice. Clin Lab. 2002;48(56):319-325. No prevalence or incidence reported. [pmid: 12071583].
Pellecchia M T, Scala R, Filla A, et al. Idiopathic cerebellar ataxia associated with celiac disease: lack of distinctive neurological features. J Neurol Neurosurg Psychiatry. 1999;66(1):32-35. No prevalence or incidence reported. [pmid: 9886447].
Pellegrini G, Scotta M S, Soardo S, et al. Elevated IgA anti-gliadin antibodies in juvenile chronic arthritis. Clin Exp Rheumatol. 1991;9(6):653-656. No prevalence or incidence reported. [pmid: 1764847].
Pena A S, Garrote J A, Crusius J B. Advances in the immunogenetics of coeliac disease. Clues for understanding the pathogenesis and disease heterogeneity. Scandinavian Journal of Gastroenterology.Supplement 1998;22556–58. No prevalence or incidence reported
Pena A S, Mann D L, Hague N E, et al. Genetic basis of gluten-sentitive enteropathy. Gastroenterology. 1978;75(2):230-235. No prevalence or incidence reported. [pmid: 307512].
Pena A S, Wijmenga C. Genetic factors underlying gluten-sensitive enteropathy. Curr Allergy Asthma Rep. 2001;1(6):526-533. No prevalence or incidence reported. [pmid: 11892082].
Pengiran Tengah D S N A, Wills A J, Holmes G K T. Neurological complications of coeliac disease. Postgrad Med J. 2002;78(921):393-398. No prevalence or incidence reported. [pmid: 12151653].
Peraaho M, Kaukinen K, Paasikivi K, et al. Wheat-starch-based gluten-free products in the treatment of newly detected coeliac disease: prospective and randomized study. Aliment Pharmacol Ther. 2003;17(4):587-594. No prevalence or incidence reported. [pmid: 12622768].
Peracchi Maddalena, Trovato Cristina, Longhi Massimo, et al. Tissue transglutaminase antibodies in patients with end-stage heart failure. Am J Gastroenterol. 2002;97(11):2850-2854. No prevalence or incidence reported. [pmid: 12425559].
Perez-Bravo F, Araya M, Mondragon A, et al. Genetic differences in HLA-DQA1* and DQB1* allelic distributions between celiac and control children in Santiago, Chile. Hum Immunol. 1999;60(3):262-267. No prevalence or incidence reported. [pmid: 10321965].
Perez-Machado Miguel A, Ashwood Paul, Thomson Michael A, et al. Reduced transforming growth factor-beta1-producing T cells in the duodenal mucosa of children with food allergy. Eur J Immunol. 2003;33(8):2307-2315. No prevalence or incidence reported. [pmid: 12884306].
Persliden J, Pettersson H B L, Falth-Magnusson K. Intestinal biopsy in children with coeliac disease; A Swedish national study of radiation dose and risk. Radiat Prot Dosim. 1995;57(14):459-462. No prevalence or incidence reported.
Persliden J, Pettersson H B, Falth-Magnusson K. Small intestinal biopsy in children with coeliac disease: measurement of radiation dose and analysis of risk. Acta Paediatr. 1993;82(3):296-299. No prevalence or incidence reported. [pmid: 8495087].
Persson L A, Ivarsson A, Hernell O. Breast-feeding protects against celiac disease in childhood--epidemiological evidence. Adv Exp Med Biol 2002;503115–123. No prevalence or incidence reported
Perticarari S, Not T, Cauci S, et al. ELISA method for quantitative measurement of IgA and IgG specific anti- gliadin antibodies. J Pediatr Gastroenterol Nutr. 1992;15(3):302-309. No prevalence or incidence reported. [pmid: 1432469].
Petaros P, Martelossi S, Tommasini A, et al. Prevalence of autoimmune disorders in relatives of patients with celiac disease. Dig Dis Sci. 2002;47(7):1427-1431. No prevalence or incidence reported. [pmid: 12141796].
Peters U, Schneeweiss S, Trautwein E A, et al. A case-control study of the effect of infant feeding on celiac disease. Ann Nutr Metab. 2001;45(4):135-142. No prevalence or incidence reported. [pmid: 11463995].
Peters Ulrike, Askling Johan, Gridley Gloria, et al. Causes of death in patients with celiac disease in a population-based Swedish cohort. Arch Intern Med. 2003;163(13):1566-1572. No prevalence or incidence reported. [pmid: 12860579].
Petronzelli F, Bonamico M, Ferrante P, et al. Genetic contribution of the HLA region to the familial clustering of coeliac disease. Ann Hum Genet. 1997;61(Pt 4):307-317. No prevalence or incidence reported. [pmid: 9365784].
Petronzelli F, Ferrante P, Triglione P, et al. Oligotyping of celiac multiplex families with the 11th International Histocompatibility Workshop reagents. Tissue Antigens. 1991;38(5):238-239. No prevalence or incidence reported. [pmid: 1780848].
Petronzelli F, Multari G, Ferrante P, et al. Different dose effect of HLA-DQ alpha beta heterodimers in insulin-dependent diabetes mellitus and celiac disease susceptibility. Hum Immunol. 1993;36(3):156-162. No prevalence or incidence reported. [pmid: 8320134].
Phillips D L, Keeffe E B. Hematologic manifestations of gastrointestinal disease. Hematol Oncol Clin North Am. 1987;1(2):207-228. No prevalence or incidence reported. [pmid: 3308821].
Phillips S, Donaldson L, Geisler K, et al. Stool composition in factitial diarrhea: a 6-year experience with stool analysis. Ann Intern Med. 1995;123(2):97-100. No prevalence or incidence reported. [pmid: 7778841].
Philotheou A. Epilogue: What have we learned to improve the treatment of children with diabetes mellitus and their families?. Journal of Pediatric Endocrinology & Metabolism - Jpem. 2001;14(Suppl 1):697-700. No prevalence or incidence reported. [pmid: 11393566].
Piattella L, Zamponi N, Cardinali C, et al. Endocranial calcifications, infantile celiac disease, and epilepsy. Child's Nervous System - Chns - Official Journal of the International Society for Pediatric Neurosurgery. 1993;9(3):172-175. No prevalence or incidence reported. [pmid: 8374923].
Picarelli A, Di Giovambattista F, Cedrone C, et al. Quantitative analysis of stool losses in adult celiac disease: use of near-infrared analysis reconsidered. Scand J Gastroenterol. 1998;33(10):1052-1056. No prevalence or incidence reported. [pmid: 9829359].
Picarelli A, Di Tola M, Sabbatella L, et al. Identification of a new coeliac disease subgroup: antiendomysial and anti-transglutaminase antibodies of IgG class in the absence of selective IgA deficiency. J Intern Med. 2001;249(2):181-188. No prevalence or incidence reported. [pmid: 11240848].
Picarelli A, Di Tola M, Sabbatella L, et al. Immunologic evidence of no harmful effect of oats in celiac disease. Am J Clin Nutr. 2001;74(1):137-140. No prevalence or incidence reported. [pmid: 11451729].
Picarelli A, Maiuri L, Frate A, et al. Production of antiendomysial antibodies after in-vitro gliadin challenge of small intestine biopsy samples from patients with coeliac disease. Lancet. 1996;348(9034):1065-1067. No prevalence or incidence reported. [pmid: 8874458].
Picarelli A, Triglione P, Mariani P, et al. Use of a threshold serum level of anti-gliadin antibodies improves diagnostic efficiency of the test in adult coeliac disease but is unreliable as a screening test. Ital J Gastroenterol. 1996;28(2):70-75. No prevalence or incidence reported. [pmid: 8781997].
Pietroletti R, Bishop A E, Carlei F, et al. Gut endocrine cell population in coeliac disease estimated by immunocytochemistry using a monoclonal antibody to chromogranin. Gut. 1986;27(7):838-843. No prevalence or incidence reported. [pmid: 3525339]. [pmcid: 1433562].
Pietzak M M, Thomas D W. Childhood malabsorption. Pediatr Rev. 2003;24(6):195-204. No prevalence or incidence reported. [pmid: 12777611].
Pistorius L R, Sweidan W H, Purdie D W, et al. Coeliac disease and bone mineral density in adult female patients. Gut. 1995;37(5):639-642. No prevalence or incidence reported. [pmid: 8549938]. [pmcid: 1382867].
Pittschieler K, Reissigl H, Mengarda G. Celiac disease in two different population groups of South Tirol. J Pediatr Gastroenterol Nutr. 1988;7(3):400-402. Not a relevant screening geography. [pmid: 3260280].
Ploski R, Ascher H, Sollid L M. HLA genotypes and the increased incidence of coeliac disease in Sweden. Scand J Gastroenterol. 1996;31(11):1092-1097. No prevalence or incidence reported. [pmid: 8938902].
Pocecco M, Ventura A. Coeliac disease and insulin-dependent diabetes mellitus: a causal association?. Acta Paediatr. 1995;84(12):1432-1433. No prevalence or incidence reported. [pmid: 8645965].
Poddar U. Celiac disease: clinical features and diagnostic criteria. Indian J Pediatr. 1999;66(1 Suppl):S21-S25. No prevalence or incidence reported. [pmid: 11132464].
Poddar Ujjal, Thapa Babu, Ram Nain, et al. Celiac disease in India: are they true cases of celiac disease?. J Pediatr Gastroenterol Nutr. 2002;35(4):508-512. Not a relevant screening geography. [pmid: 12394375].
Podolsky D K, LaMont J T. So, where are all the celiacs?. Gastroenterology. 1999;116(2):237. No prevalence or incidence reported.
Polanco I, Mearin M L, Larrauri J, et al. Effect of gluten supplementation in healthy siblings of children with celiac disease. Gastroenterology. 1987;92(3):678-681. No prevalence or incidence reported. [pmid: 3817390].
Poley J R, Bhatia M, Welsh J D. Disaccharidase deficiency in infants with cow's milk protein intolerance. Response to treatment. Digestion. 1978;17(2):97-107. No prevalence or incidence reported. [pmid: 627328].
Polvi A, Arranz E, Fernandez-Arquero M, et al. HLA-DQ2-Negative Celiac disease in Finland and Spain. Hum Immunol. 1998;59(3):169-175. No prevalence or incidence reported. [pmid: 9548076].
Polvi A, Garden O A, Elwood C M, et al. Canine major histocompatibility complex genes DQA and DQB in Irish setter dogs. Tissue Antigens. 1997;49(3 Pt 1):236-243. No prevalence or incidence reported. [pmid: 9098930].
Polvi A, Maki M, Collin P, et al. TNF microsatellite alleles a2 and b3 are not primarily associated with celiac disease in the Finnish population. Tissue Antigens. 1998;51(5):553-555. No prevalence or incidence reported. [pmid: 9672155].
Polvi A, Maki M, Partanen J. Celiac patients predominantly inherit HLA-DPB1*0101 positive haplotype from HLA-DQ2 homozygous parent. Hum Immunol. 1997;53(2):156-158. No prevalence or incidence reported. [pmid: 9129973].
Poolman M, Hough S. Diabetic diarrhoea - A neglected complication. J Endocrinol Metab Diabetes S Afr. 2003;8(2):52-59. No prevalence or incidence reported.
Poon E, Nixon R. Cutaneous spectrum of coeliac disease. Australas J Dermatol. 2001;42(2):136-138. No prevalence or incidence reported. [pmid: 11309040].
Popat S, Hearle N, Bevan S, et al. Mutational analysis of CD28 in coeliac disease. Scand J Gastroenterol. 2002;37(5):536-539. No prevalence or incidence reported. [pmid: 12059054].
Popat S, Hearle N, Hogberg L, et al. Variation in the CTLA4/CD28 gene region confers an increased risk of coeliac disease. Ann Hum Genet. 2002;66(Pt 2):125-137. No prevalence or incidence reported. [pmid: 12174216].
Popat S, Hearle N, Wixey J, et al. Analysis of the CTLA4 gene in Swedish coeliac disease patients. Scand J Gastroenterol. 2002;37(1):28-31. No prevalence or incidence reported. [pmid: 11843030].
Popat S, Hogberg L, McGuire S, et al. Germline mutations in TGM2 do not contribute to coeliac disease susceptibility in the Swedish population. Eur J Gastroenterol Hepatol. 2001;13(12):1477-1479. No prevalence or incidence reported. [pmid: 11742196].
Porter K G, McMaster D, Elmes M E et al. Anemia and low serum-copper during zinc therapy. Lancet 1977;2(8041):774No prevalence or incidence reported
Postel-Vinay M C, Saab C, Gourmelen M. Nutritional status and growth hormone-binding protein. Horm Res. 1995;44(4):177-181. No prevalence or incidence reported. [pmid: 8522280].
Prasad S, Thomas P, Nicholas D S, et al. Adult endomysial antibody-negative coeliac disease and cigarette smoking. Eur J Gastroenterol Hepatol. 2001;13(6):667-671. No prevalence or incidence reported. [pmid: 11434592].
Pratesi R, Gandolfi L, Friedman H, et al. Serum IgA antibodies from patients with coeliac disease react strongly with human brain blood-vessel structures. Scand J Gastroenterol. 1998;33(8):817-821. No prevalence or incidence reported. [pmid: 9754728].
Pratesi R, Gandolfi L, Garcia S G, et al. Prevalence of coeliac disease: Unexplained age-related variation in the same population. Scand J Gastroenterol. 2003;38(7):747-750. Not a relevant screening geography. [pmid: 12889561].
Pratesi R, Gandolfi L, Garcia S G, et al. Prevalence of coeliac disease: Unexplained age-related variation in the same population. Scand J Gastroenterol. 2003;38(7):747-750. Not a relevant screening geography. [pmid: 12889561].
Pratesi Riccardo, Gandolfi Lenora, Martins Rita C, et al. Is the prevalence of celiac disease increased among epileptic patients?. Arq Neuropsiquiatr. 2003;61(2b):330-334. No prevalence or incidence reported. [pmid: 12894262].
Prati D, Bardella M T, Peracchi M, et al. High frequency of anti-endomysial reactivity in candidates to heart transplant. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(1):39-43. No prevalence or incidence reported. [pmid: 11926572].
Pratico G, Caltabiano L, Bottaro G, et al. Serum levels of osteocalcin and type I procollagen in children with celiac disease. J Pediatr Gastroenterol Nutr. 1997;24(2):170-173. No prevalence or incidence reported. [pmid: 9106103].
Presotto F, Betterle C. Insulin-dependent diabetes mellitus: A constellation of autoimmune diseases. Journal of Pediatric Endocrinology & Metabolism - Jpem. 1997;10(5):455-469. No prevalence or incidence reported. [pmid: 9401901].
Prichard M G, Ryan G, Musk A W. Wheat flour sensitisation and airways disease in urban bakers. Br J Ind Med. 1984;41(4):450-454. No prevalence or incidence reported. [pmid: 6498109].
Pricolo V E, Mangi A A, Aswad B, et al. Gastrointestinal malignancies in patients with celiac sprue. Am J Surg. 1998;176(4):344-347. No prevalence or incidence reported. [pmid: 9817252].
Primack S L, Miller R R, Muller N L. Diffuse pulmonary hemorrhage: Clinical, pathologic, and imaging features. Am J Roentgenol. 1995;164(2):295-300. No prevalence or incidence reported. [pmid: 7839958].
Primignani M, Agape D, Ronchi G, et al. Prevalence of duodenal and jejunal lesions in dermatitis herpetiformis. Ric Clin Lab. 1987;17(3):243-249. No prevalence or incidence reported. [pmid: 3671997].
Prince M I, Jones D E J. Primary biliary cirrhosis: New perspectives in diagnosis and treatment. Postgrad Med J. 2000;76(894):199-206. No prevalence or incidence reported. [pmid: 10727561].
Probert C S, Mayberry J F, Mann R. Inflammatory bowel disease in the rural Indian subcontinent: a survey of patients attending mission hospitals. Digestion. 1990;47(1):42-46. No prevalence or incidence reported. [pmid: 2292348].
Procaccini E, Chianelli M, Pantano P, et al. Imaging of autoimmune diseases. Q J Nucl Med. 1999;43(1):100-112. No prevalence or incidence reported. [pmid: 10230286].
Pruessner H T. Detecting celiac disease in your patients. Am Fam Physician. 1998;57(5):102334-1039. No prevalence or incidence reported. [pmid: 9518950].
Pryce D, Behrens R, Davidson R, et al. Onchocerciasis in members of an expedition to Cameroon: Role of advice before travel and long term follow up. Br Med J. 1992;304(6837):1285-1286. No prevalence or incidence reported. [pmid: 1606433].
Pueschel S M, Romano C, Failla P, et al. A prevalence study of celiac disease in persons with Down syndrome residing in the United States of America. Acta Paediatr. 1999;88(9):953-956. Not a relevant screening group. [pmid: 10519335].
Pynnonen P, Isometsa E, Aalberg V, et al. Is coeliac disease prevalent among adolescent psychiatric patients?. Acta Paediatrica. 2002;91(6):657-659. Not sensitivity or specificity of an identified test. [pmid: 12162597].
Qari F A. Clinical presentation of adult celiac disease in Western Saudi Arabia. Saudi Med J. 2002;23(12):1514-1517. No prevalence or incidence reported. [pmid: 12518204].
Quisel Anna, Gill James M, Westerberg Dyanne. Guideline for diagnosis of celiac disease. Del Med J. 2002;74(5):229-241. No prevalence or incidence reported. [pmid: 12063834].
Rabassa E B, Sagaro E, Fragoso T, et al. Coeliac disease in Cuban children. Arch Dis Child. 1981;56(2):128-131. Not a relevant screening geography. [pmid: 7469463].
Rabinowitz L G, Esterly N B. Inflammatory bullous diseases in children. Dermatol Clin. 1993;11(3):565-581. No prevalence or incidence reported. [pmid: 8365040].
Raccuglia G, French A, Zarafonetis C J. Absorption and excretion of cyanocobalamine after oral administration of a large dose in various conditions. Acta Haematol. 1969;42(1):1-7. No prevalence or incidence reported. [pmid: 4982617].
Radzikowski A, Kulus M, Krauze A, et al. Growth, bone age and nutritional status in neglected coeliac disease. Materia Medica Polona. Polish Journal of Medicine and Pharmacy. 1991;23(2):146-150. No prevalence or incidence reported. [pmid: 1842603].
Raffensperger E C, D'Agostino F, Manfredo H, et al. Fecal fat excretion. An analysis of four years' experience. Arch Intern Med. 1967;119(6):573-576. No prevalence or incidence reported. [pmid: 6027184].
Ralston S H, Willocks L, Pitkeathly D A, et al. High prevalence of unrecognized osteomalacia in hospital patients with rheumatoid arthritis. Br J Rheumatol. 1988;27(3):202-205. No prevalence or incidence reported. [pmid: 3378124].
Ramalingaswami V. Interface of protein nutrition and medicine in the tropics. Lancet. 1969;2(7623):733-736. No prevalence or incidence reported. [pmid: 4186178].
Ramos-Arroyo M A, Feijoo E, Sanchez-Valverde F, et al. Heat-shock protein 70–1 and HLA class II gene polymorphisms associated with celiac disease susceptibility in Navarra (Spain). Hum Immunol. 2001;62(8):821-825. No prevalence or incidence reported. [pmid: 11476906].
Ramos-Remus C, Bahlas S, Vaca-Morales O. Rheumatic features of gastrointestinal tract, hepatic, and pancreatic diseases. Curr Opin Rheumatol. 1997;9(1):56-61. No prevalence or incidence reported. [pmid: 9110135].
Ramot B, Many A. Primary intestinal lymphoma: clinical manifestations and possible effect of environmental factors. Recent Results in Cancer Research.Fortschritte Der Krebsforschung.Progres Dans Les Recherches Sur Le Cancer 1972;39193–199. No prevalence or incidence reported
Rampertab S D, Forde K A, Green P H R. Small bowel neoplasia in coeliac disease. Gut. 2003;52(8):1211-1214. No prevalence or incidence reported. [pmid: 12865284]. [pmcid: 1773745].
Rannem T, Hylander E, Jarnum S, et al. Calcium absorption and bone mineral content in patients subjected to ileal bypass because of familial hypercholesterolaemia. Scand J Gastroenterol. 1990;25(9):897-905. No prevalence or incidence reported. [pmid: 2218396].
Rapoport M J, Bistritzer T, Vardi O, et al. Increased prevalence of diabetes-related autoantibodies in celiac disease. J Pediatr Gastroenterol Nutr. 1996;23(5):524-527. No prevalence or incidence reported. [pmid: 8985839].
Rasmusson C G, Eriksson M A. Celiac disease and mineralisation disturbances of permanent teeth. International Journal of Paediatric Dentistry / the British Paedodontic Society and the International Association of Dentistry for Children. 2001;11(3):179-183. No prevalence or incidence reported. [pmid: 11484467].
Ratnam K V. IgA dermatosis in an adult Chinese population. A 10-year study of linear IgA and dermatitis herpetiformis in Singapore. Int J Dermatol. 1988;27(1):21-24. No prevalence or incidence reported. [pmid: 3278990].
Ratsch I M, Catassi C. Coeliac disease: a potentially treatable health problem of Saharawi refugee children. Bull World Health Organ. 2001;79(6):541-545. No prevalence or incidence reported. [pmid: 11436476].
Rautonen J, Rautonen N, Savilahti E. Antibodies to gliadin in children with coeliac disease. Acta Paediatr Scand. 1991;80(12):1200-1206. No prevalence or incidence reported. [pmid: 1785292].
Ravaglia Giovanni, Forti Paola, Maioli Fabiola, et al. Increased prevalence of coeliac disease in autoimmune thyroiditis is restricted to aged patients. Exp Gerontol. 2003;38(5):589-595. No prevalence or incidence reported. [pmid: 12742537].
Ravelli A M, Tobanelli P, Minelli L, et al. Endoscopic features of celiac disease in children. Gastroenterol Int. 2001;54(6):736-742. No prevalence or incidence reported.
Rawashdeh M O, Khalil B, Raweily E. Celiac disease in Arabs. J Pediatr Gastroenterol Nutr. 1996;23(4):415-418. No prevalence or incidence reported. [pmid: 8956178].
Rea F, Polito C, Marotta A, et al. Restoration of body composition in celiac children after one year of gluten-free diet. J Pediatr Gastroenterol Nutr. 1996;23(4):408-412. No prevalence or incidence reported. [pmid: 8956176].
Read M, O'Halloran E T, O'sullivan C. Coeliac disease in adolescents/young adults: difficulties in monitoring. Br J Biomed Sci. 2000;57(3):217-221. No prevalence or incidence reported. [pmid: 11050774].
Reeder M M. RPC of the month from AFIP. Radiology. 1969;93(2):427-433. No prevalence or incidence reported. [pmid: 5363393].
Reen D J, O'Regan D. HLA antigen frequencies in an Irish population. Tissue Antigens. 1980;15(4):369-372. No prevalence or incidence reported. [pmid: 7466782].
Rees T D, Binnie W H. Recurrent aphthous stomatitis. Dermatol Clin. 1996;14(2):243-256. No prevalence or incidence reported. [pmid: 8725581].
Reeves G E, Burns C, Hall S T, et al. The measurement of IgA and IgG transglutaminase antibodies in celiac disease: a comparison with current diagnostic methods. Pathology. 2000;32(3):181-185. No prevalence or incidence reported. [pmid: 10968391].
Reibel S, Rohr C, Ziegert M, et al. What safety measures need to be taken in oral food challenges in children?. Allergy. 2000;55(10):940-944. No prevalence or incidence reported. [pmid: 11030374].
Reijonen H, Ilonen J, Knip M, et al. Insulin-dependent diabetes mellitus associated with dermatitis herpetiformis: evidence for heterogeneity of HLA-associated genes. Tissue Antigens. 1991;37(2):94-96. No prevalence or incidence reported. [pmid: 2057939].
Reiner E B, Patterson M. Intestinal disaccharidase content. South Med J. 1966;59(3):311-314. No prevalence or incidence reported. [pmid: 5910634].
Rejman F. Postgastrectomy syndrome. A clinical study based upon 100 patients. Annales Chirurgiae Et Gynaecologiae Fenniae.Supplementum 1970;1701–63. No prevalence or incidence reported
Rensch M J, Szyjkowski R, Shaffer R T, et al. The prevalence of celiac disease autoantibodies in patients with systemic lupus erythematosus. Am J Gastroenterol. 2001;96(4):1113-1115. No prevalence or incidence reported. [pmid: 11316156].
Rettenbacher T, Hollerweger A, Macheiner P, et al. Adult celiac disease: US signs. Radiology. 1999;211(2):389-394. No prevalence or incidence reported. [pmid: 10228518].
Reunala T L, Koskimies S. Familial dermatitis herpetiformis. Clin Dermatol. 1991;9(3):335-339. No prevalence or incidence reported. [pmid: 1806220].
Reunala T L. Dermatitis herpetiformis. Clin Dermatol. 2001;19(6):728-736. No prevalence or incidence reported. [pmid: 11705682].
Reunala T, Collin P. Diseases associated with dermatitis herpetiformis. Br J Dermatol. 1997;136(3):315-318. No prevalence or incidence reported. [pmid: 9115907].
Reunala T, Lokki J. Dermatitis herpetiformis in Finland. Acta Derm Venereol. 1978;58(6):505-510. No prevalence or incidence reported. [pmid: 83074].
Reunala T, Salo O P, Tiilikainen A, et al. Family studies in dermatitis herpetiformis. Ann Clin Res. 1976;8(4):254-261. No prevalence or incidence reported. [pmid: 999211].
Reunala T. Dermatitis herpetiformis: coeliac disease of the skin. Ann Med. 1998;30(5):416-418. No prevalence or incidence reported. [pmid: 9814827].
Reunala T. Incidence of familial dermatitis herpetiformis. Br J Dermatol. 1996;134(3):394-398. No prevalence or incidence reported. [pmid: 8731659].
Reyes H, Radrigan M E, Gonzalez M C, et al. Steatorrhea in patients with intrahepatic cholestasis of pregnancy. Gastroenterology. 1987;93(3):584-590. No prevalence or incidence reported. [pmid: 3609667].
Rhim G S, McMorris M S. School readiness for children with food allergies. Annals of Allergy, Asthma & Immunology - Official Publication of the American College of Allergy, Asthma, & Immunology. 2001;86(2):172-176. No prevalence or incidence reported. [pmid: 11258686].
Ribeiro U, Posner M C, Safatle-Ribeiro A V, et al. Risk factors for squamous cell carcinoma of the oesophagus. Br J Surg. 1996;83(9):1174-1185. No prevalence or incidence reported. [pmid: 8983603].
Ribes C, Pena A S, Pereda A, et al. IGA gliadin antibodies, a useful screening test for coeliac disease in family members of children with coeliac disease. J Clin Nutr Gastroenterol. 1991;6(4):196-202. Unable to obtain full article.
Ribes-Koninckx C, Alfonso P, Ortigosa L, et al. A beta-turn rich oats peptide as an antigen in an ELISA method for the screening of coeliac disease in a paediatric population. Eur J Clin Invest. 2000;30(8):702-708. No prevalence or incidence reported. [pmid: 10964162].
Riccabona M, Rossipal E. Sonographic findings in celiac disease. J Pediatr Gastroenterol Nutr. 1993;17(2):198-200. No prevalence or incidence reported. [pmid: 8229548].
Rich E J, Christie D L. Anti-gliadin antibody panel and xylose absorption test in screening for celiac disease. J Pediatr Gastroenterol Nutr. 1990;10(2):174-178. No prevalence or incidence reported. [pmid: 2182821].
Rifkind E A, Logan R F A, Busuttil A. Coeliac disease in Edinburgh and the Lothians 1900-1980. Scott Med J 1982;27(4):342No prevalence or incidence reported
Rifkind E A, Logan R F, Busuttil A et al. Coeliac disease in Edinburgh and the Lothians 1900-1980. Scott Med J 1982;27(3):256Serology screen <1990
Riggs B L, Kelly P J, Kinney W R, et al. Calcium deficiency and osteoporosis. Observations in one hundred and sixty-six patients and critical review of the literature. Journal of Bone and Joint Surgery. American Volume. 1967;49(5):915-924. No prevalence or incidence reported.
Riley D. Changing paediatrics. 18 years admissions to a medical unit. Scott Med J. 1968;13(5):159-161. No prevalence or incidence reported. [pmid: 5301606].
Riordan S M, McIver C J, Duncombe V M, et al. Factors influencing the 1-g 14C-D-xylose breath test for bacterial overgrowth. Am J Gastroenterol. 1995;90(9):1455-1460. No prevalence or incidence reported. [pmid: 7661169].
Risch N. Assessing the role of HLA-linked and unlinked determinants of disease. Am J Hum Genet. 1987;40(1):1-14. No prevalence or incidence reported. [pmid: 3618593]. [pmcid: 1684002].
Rizzetto M, Bonino F, Pera A, et al. Incidence and significance of different types of connective tissue antibodies in adult and pediatric gastroenterological disorders. Digestion. 1978;17(1):29-37. No prevalence or incidence reported. [pmid: 342322].
Robbana-Barnat S, Fradin J. Cereal grains: IgE- and non-IgE-mediated reactions. J Nutr Environ Med. 1997;7(1):35-46. No prevalence or incidence reported.
Robert M E, Ament M E, Weinstein W M. The histologic spectrum and clinical outcome of refractory and unclassified sprue. Am J Surg Pathol. 2000;24(5):676-687. No prevalence or incidence reported. [pmid: 10800986].
Robinson B N, Roberts D F, Mather B A, et al. Coeliac disease and HLA: a family study. J Immunogenet. 1980;7(5):381-391. No prevalence or incidence reported. [pmid: 7430678].
Robinson F. FLAIR-FLOW 4: Synthesis report on food allergy for health professionals. Nutr Bull. 2002;27(2):85-92. No prevalence or incidence reported.
Robinson F. Producing foods for consumers with food allergy. Nutr Bull. 2003;28(1):65-67. No prevalence or incidence reported.
Robles D T, Fain P R, Gottlieb P A, et al. The genetics of autoimmune polyendocrine syndrome type II. Endocrinol Metab Clin North Am. 2002;31(2):353-368. No prevalence or incidence reported. [pmid: 12092455].
Rogers E L, Douglass W, Russell R M, et al. Deficiency of fat soluble vitamins after jejunoileal bypass surgery for morbid obesity. Am J Clin Nutr. 1980;33(6):1208-1214. No prevalence or incidence reported. [pmid: 7386410].
Roizen Nancy J, Patterson David. Down Syndrome. Lancet. 2003;361(9365):1281-1289. No prevalence or incidence reported. [pmid: 14511944].
Roldan M B, Alonso M, Barrio R. Thyroid autoimmunity in children and adolescents with Type 1 diabetes mellitus. Diabetes Nutr Metab. 1999;12(1):27-31. No prevalence or incidence reported. [pmid: 10517303].
Romiti A, Merli M, Martorano M, et al. Malabsorption and nutritional abnormalities in patients with liver cirrhosis. Ital J Gastroenterol. 1990;22(3):118-123. No prevalence or incidence reported. [pmid: 2131941].
Rona R J, Tanner J M. Aetiology of idiopathic growth hormone deficiency in England and Wales. Arch Dis Child. 1977;52(3):197-208. No prevalence or incidence reported. [pmid: 848998].
Rosa Utiyama S R, Silva Kotze L M, Nisihara R M, et al. Spectrum of autoantibodies in celiac patients and relatives. Dig Dis Sci. 2001;46(12):2624-2630. No prevalence or incidence reported. [pmid: 11768251].
Roschger P, Fratzl P, Eschberger J, et al. Validation of quantitative backscattered electron imaging for the measurement of mineral density distribution in human bone biopsies. Bone. 1998;23(4):319-326. No prevalence or incidence reported. [pmid: 9763143].
Roschmann E, Wienker T F, Gerok W et al. Analysis of marker genes contributing to coeliac disease susceptibility. Adv Exp Med Biol 1995;371b1339–1343. No prevalence or incidence reported
Roschmann E, Wienker T F, Gerok W, et al. T-cell receptor variable genes and genetic susceptibility to celiac disease: an association and linkage study. Gastroenterology. 1993;105(6):1790-1796. No prevalence or incidence reported. [pmid: 8253354].
Roschmann E, Wienker T F, Volk B A. Role of T cell receptor delta gene in susceptibility to celiac disease. J Mol Med. 1996;74(2):93-98. No prevalence or incidence reported. [pmid: 8820404].
Rose G A. Clinical aspects of calcium metabolism. Bone diseases. Trans Med Soc Lond 1970;8662–71. No prevalence or incidence reported
Rosenberg W M, Wordsworth B P, Jewell D P, et al. A locus telomeric to HLA-DPB encodes susceptibility to coeliac disease. Immunogenetics. 1989;30(4):307-310. No prevalence or incidence reported. [pmid: 2571589].
Ross J R. Postgastrectomy syndromes and their management. Surg Clin North Am. 1971;51(3):615-632. No prevalence or incidence reported. [pmid: 5314204].
Rossi E. Monosymptomatic forms of celiac disease. Eur J Pediatr. 1982;138(1):4-5. No prevalence or incidence reported. [pmid: 6756926].
Rossiter M A, Barrowman J A, Dand A, et al. Amylase content of mixed saliva in children. Acta Paediatr Scand. 1974;63(3):389-392. No prevalence or incidence reported. [pmid: 4209508].
Ross-Smith P, Jenner F A. Diet (gluten) and schizophrenia. J Hum Nutr. 1980;34(2):107-112. No prevalence or incidence reported. [pmid: 6989901].
Rostami K, Mulder C J J. Coeliac disease. A challenging diagnosis. Rom J Gastroenterol. 1999;8(2):111-114. No prevalence or incidence reported.
Rostami K, Steegers E A, Wong W Y, et al. Coeliac disease and reproductive disorders: a neglected association. Eur J Obstet Gynecol Reprod Biol. 2001;96(2):146-149. No prevalence or incidence reported. [pmid: 11384797].
Rostoker G, Delchier J C, Chaumette M T. Increased intestinal intra-epithelial T lymphocytes in primary glomerulonephritis: a role of oral tolerance breakdown in the pathophysiology of human primary glomerulonephritides?. Nephrology, Dialysis, Transplantation - Official Publication of the European Dialysis and Transplant Association - European Renal Association. 2001;16(3):513-517. No prevalence or incidence reported. [pmid: 11239024].
Rotter J I, Landaw E M. Measuring the genetic contribution of a single locus to a multilocus disease. Clin Genet. 1984;26(6):529-542. No prevalence or incidence reported. [pmid: 6541983].
Rovner Alisha J, Schall Joan I, Jawad Abbas F, et al. Rethinking growth failure in Alagille syndrome: the role of dietary intake and steatorrhea. J Pediatr Gastroenterol Nutr. 2002;35(4):495-502. No prevalence or incidence reported. [pmid: 12394373].
Roy P K, Venzon D J, Feigenbaum K M, et al. Gastric secretion in Zollinger-Ellison syndrome. Correlation with clinical expression, tumor extent and role in diagnosis--a prospective NIH study of 235 patients and a review of 984 cases in the literature. Medicine. 2001;80(3):189-222. No prevalence or incidence reported. [pmid: 11388095].
Roy R N, Russell R I. Crohn's disease & aflatoxins. J R Soc Health. 1992;112(6):277-279. No prevalence or incidence reported. [pmid: 1469674].
Rude R K, Olerich M. Magnesium deficiency: possible role in osteoporosis associated with gluten-sensitive enteropathy. Osteoporosis International - a Journal Established as Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the Usa. 1996;6(6):453-461. No prevalence or incidence reported. [pmid: 9116391].
Rueda B, Pascual M, Lopez-Nevot M A, et al. A new allele within the transmembrane region of the human MICA gene with seven GCT repeats. Tissue Antigens. 2002;60(6):526-528. No prevalence or incidence reported. [pmid: 12542746].
Rueda B, Pascual M, Lopez-Nevot M A, et al. Association of MICA-A5. 1 allele with susceptibility to celiac disease in a family study. American Journal of Gastroenterology. 2003;98(2):359-362. Not sensitivity or specificity of an identified test. [pmid: 12591055].
Rueda Blanca, Lopez-Nevot Miguel, Angel Pascual, et al. Polymorphism of the inducible nitric oxide synthase gene in celiac disease. Hum Immunol. 2002;63(11):1062-1065. No prevalence or incidence reported. [pmid: 12392860].
Ruiz del, Prado M Y, Olivares Lopez J L, et al. HLA system. Phenotypic and gene frequencies in celiac and healthy subjects from the same geographical area. Revista Espanola De Enfermedades Digestivas - Organo Oficial De La Sociedad Espanola De Patologia Digestiva. 2001;93(2):106-113. No prevelence or incidence reported. [pmid: 11471223].
Ruiz M Y, Olivares J L. Three-loci HLA haplotypes in Spanish celiac children and healthy subjects: estimation of linkage disequilibrium and haplotype frequencies. Am J Gastroenterol. 2001;96(5):1455-1459. No prevalence or incidence reported. [pmid: 11374682].
Rumbo M, Chirdo F G, Ben R, et al. Evaluation of coeliac disease serological markers in Down syndrome patients. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(2):116-121. No prevalence or incidence reported. [pmid: 11926554].
Ruskone-Fourmestraux A, Rambaud J C. Gastrointestinal lymphoma: prevention and treatment of early lesions. Best Practice & Research. Clinical Gastroenterology. 2001;15(2):337-354. No prevalence or incidence reported. [pmid: 11355919].
Russo M W, Fried M W. Side effects of therapy for chronic hepatitis C. Gastroenterology. 2003;124(6):1711-1719. No prevalence or incidence reported. [pmid: 12761728].
Russo P A, Chartrand L J, Seidman E. Comparative analysis of serologic screening tests for the initial diagnosis of celiac disease. Pediatrics. 1999;104(1 Pt 1):75-78. No prevalence or incidence reported. [pmid: 10390263].
Ryan J. Coeliac disease. Update 2000. Aust Fam Physician. 2000;29(9):835-838. No prevalence or incidence reported. [pmid: 11008385].
Ryder L P, Staub Nielsen L, Svejgaard A. Associations between HL A histocompatibility antigens and non malignant diseases. Humangenetik. 1974;25(4):251-264. No prevalence or incidence reported. [pmid: 4618833].
Saalman R, Fallstrom S P. High incidence of urinary tract infection in patients with coeliac disease. Arch Dis Child. 1996;74(2):170-171. No prevalence or incidence reported. [pmid: 8660085].
Sabra Aderbal, Bellanti Joseph A, Rais Jonathan, et al. IgE and non-IgE food allergy. Annals of Allergy, Asthma & Immunology - Official Publication of the American College of Allergy, Asthma, & Immunology. 2003;90(6 Suppl 3):71-76. No prevalence or incidence reported. [pmid: 12839123].
Sachdev A, Srinivasan V, Maheswary S, et al. Adult onset celiac disease in north India. Tropical Gastroenterology - Official Journal of the Digestive Diseases Foundation. 2002;23(3):117-119. No prevalence or incidence reported. [pmid: 12693151].
Sagaro E, Jimenez N. Family studies of coeliac disease in Cuba. Arch Dis Child. 1981;56(2):132-133. Not a relevant screening geography. [pmid: 7469464].
Salmela M T, Pender S L, Reunala T, et al. Parallel expression of macrophage metalloelastase (MMP-12) in duodenal and skin lesions of patients with dermatitis herpetiformis. Gut. 2001;48(4):496-502. No prevalence or incidence reported. [pmid: 11247893]. [pmcid: 1728241].
Salur L, Uibo O, Talvik I, et al. The high frequency of coeliac disease among children with neurological disorders. European Journal of Neurology - the Official Journal of the European Federation of Neurological Societies. 2000;7(6):707-711. No prevalence or incidence reported. [pmid: 11136360].
Salvati V M, Bajaj-Elliott M, Poulsom R, et al. Keratinocyte growth factor and coeliac disease. Gut. 2001;49(2):176-181. No prevalence or incidence reported. [pmid: 11454791]. [pmcid: 1728384].
Salvetti M, Ristori G, Bomprezzi R, et al. Twins: Mirrors of the immune system. Immunol Today. 2000;21(7):342-347. No prevalence or incidence reported. [pmid: 10871876].
Sampson H A, Scanlon S M. Natural history of food hypersensitivity in children with atopic dermatitis. Eur J Pediatr. 1989;115(1):23-27. No prevalence or incidence reported.
Sampson H A. Food allergy. Curr Opin Immunol. 1990;2(4):542-547. No prevalence or incidence reported. [pmid: 2700896].
Sampson H A. Patient's perception of food allergy may not jibe with reality. Consultant 1997;37(2):226+233No prevalence or incidence reported
Sampson H A. Utility of food-specific IgE concentrations in predicting symptomatic food allergy. J Allergy Clin Immunol. 2001;107(5):891-896. No prevalence or incidence reported. [pmid: 11590398].
Sanchez D, Tuckova L, Sebo P, et al. Occurrence of IgA and IgG autoantibodies to calreticulin in coeliac disease and various autoimmune diseases. J Autoimmun. 2000;15(4):441-449. No prevalence or incidence reported. [pmid: 11090243].
Sanchez-Albisua Iciar, Storm Wolfgang, Wascher Iris, et al. How frequent is coeliac disease in Down syndrome?. Eur J Pediatr. 2002;161(12):683-684. Not a relevant screening group. [pmid: 12536992].
Sanchez-Borges M, Capriles-Hulett A, Suarez-Chacon R, et al. Oral anaphylaxis from mite ingestion. Allergy Clin Immunol Int. 2001;13(1):33-35. No prevalence or incidence reported.
Sandberg-Bennich S, Dahlquist G, Kallen B. Coeliac disease is associated with intrauterine growth and neonatal infections. Acta Paediatr. 2002;91(1):30-33. No prevalence or incidence reported. [pmid: 11883814].
Sanders D S, Carter M J, Hurlstone D P, et al. Association of adult coeliac disease with irritable bowel syndrome: a case-control study in patients fulfilling ROME II criteria referred to secondary care. Lancet. 2001;358(9292):1504-1508. No prevalence or incidence reported. [pmid: 11705563].
Sanders D S, Hurlstone D P, Stokes R O, et al. Changing face of adult coeliac disease: experience of a single university hospital in South Yorkshire. Postgrad Med J. 2002;78(915):31-33. Not a relevant screening test. [pmid: 11796869].
Sanders D S. Coeliac disease. Br J Surg. 2002;89(6):676-677. Review article. [pmid: 12027975].
Saredi N, Bava J. Cryptosporidiosis in pediatric patients. Rev Inst Med Trop Sao Paulo. 1998;40(3):197-200. No prevalence or incidence reported. [pmid: 9830736].
Sari Ramazan, Aydogdu Ismet, Sevinc Alper, et al. Upper and lower gastrointestinal endoscopical investigation in elderly patients with iron deficiency anaemia. Haematologia (Budap). 2002;31(4):327-332. Not a relevant screening geography. [pmid: 12038516].
Sategna Guidetti C, Solerio E, Scaglione N, et al. Duration of gluten exposure in adult coeliac disease does not correlate with the risk for autoimmune disorders. Gut. 2001;49(4):502-505. No prevalence or incidence reported. [pmid: 11559646]. [pmcid: 1728461].
Sategna Guidetti, Carla Scaglione, Nadia Martini, et al. Red cell distribution width as a marker of coeliac disease: a prospective study. Eur J Gastroenterol Hepatol. 2002;14(2):177-181. No prevalence or incidence reported. [pmid: 11981342].
Sategna-Guidetti C, Bianco L, Riffero P. Is watery diarrhoea a feature of distal ileum resection in Crohn's disease female patients?. Panminerva Med. 1987;29(3):189-190. No prevalence or incidence reported. [pmid: 3696752].
Sategna-Guidetti C, Bruno M, Mazza E, et al. Autoimmune thyroid diseases and coeliac disease. Eur J Gastroenterol Hepatol. 1998;10(11):927-931. No prevalence or incidence reported. [pmid: 9872614].
Sategna-Guidetti C, Ferfoglia G, Bruno M, et al. Do IgA antigliadin and IgA antiendomysium antibodies show there is latent coeliac disease in primary IgA nephropathy?. Gut. 1992;33(4):476-478. No prevalence or incidence reported. [pmid: 1582590]. [pmcid: 1374062].
Sategna-Guidetti C, Grosso S B, Grosso S, et al. The effects of 1-year gluten withdrawal on bone mass, bone metabolism and nutritional status in newly-diagnosed adult coeliac disease patients. Aliment Pharmacol Ther. 2000;14(1):35-43. No prevalence or incidence reported. [pmid: 10632643].
Sategna-Guidetti C, Grosso S, Bruno M, et al. Reliability of immunologic markers of celiac sprue in the assessment of mucosal recovery after gluten withdrawal. J Clin Gastroenterol. 1996;23(2):101-104. No prevalence or incidence reported. [pmid: 8877634].
Sategna-Guidetti C, Grosso S. Changing pattern in adult coeliac disease: A 24-year survey. Eur J Gastroenterol Hepatol. 1994;6(1):15-19. Not a relevant screening test.
Sategna-Guidetti C, Volta U, Ciacci C, et al. Prevalence of thyroid disorders in untreated adult celiac disease patients and effect of gluten withdrawal: an Italian multicenter study. Am J Gastroenterol. 2001;96(3):751-757. No prevalence or incidence reported. [pmid: 11280546].
Saukkonen T, Ilonen J, Akerblom H K, et al. Prevalence of coeliac disease in siblings of patients with Type I diabetes is related to the prevalence of DQB1*02 allele. Diabetologia. 2001;44(8):1051-1053. Not a relevant screening group. [pmid: 11484084].
Saukkonen T, Vaisanen S, Akerblom H K, et al. Coeliac disease in children and adolescents with type 1 diabetes: a study of growth, glycaemic control, and experiences of families. Acta Paediatr. 2002;91(3):297-302. No prevalence or incidence reported. [pmid: 12022302].
Savage D A, Middleton D, Trainor F, et al. HLA class II frequencies in celiac disease patients in the west of Ireland. Hum Immunol. 1992;34(1):47-52. No prevalence or incidence reported. [pmid: 1356956].
Saviana B, Quilliot D, Ziegler O, et al. Diagnosis of lipid malabsorption in patients with chronic pancreatitis: a new indirect test using postprandial plasma apolipoprotein B-48. Am J Gastroenterol. 1999;94(11):3229-3235. No prevalence or incidence reported. [pmid: 10566720].
Savidge T C, Shmakov A N, Walker-Smith J A, et al. Epithelial cell proliferation in childhood enteropathies. Gut. 1996;39(2):185-193. No prevalence or incidence reported. [pmid: 8977336]. [pmcid: 1383296].
Savilahti E, Ormala T, Saukkonen T, et al. Jejuna of patients with insulin-dependent diabetes mellitus (IDDM) show signs of immune activation. Clin Exp Immunol. 1999;116(1):70-77. No prevalence or incidence reported. [pmid: 10209507]. [pmcid: 1905225].
Savilahti E, Simell O, Koskimies S, et al. Celiac disease in insulin-dependent diabetes mellitus. Eur J Pediatr. 1986;108(5 Pt 1):690-693. Serology screen <1990.
Savilahti E, Verkasalo M. Intestinal cow's milk allergy: pathogenesis and clinical presentation. Clin Rev Allergy. 1984;2(1):7-23. No prevalence or incidence reported. [pmid: 6370413].
Sawhney I M S, Chopra J S. Occipital seizures and epilepsies in children. Neurol India. 1994;42(2):92. No prevalence or incidence reported.
Scalici C, Manzoni D, Licastro G, et al. Celiac disease in the pediatric age, psychological difficulties experienced on the gluten-free diet. A preliminary investigation at the Clinic for Celiac Disease of the “G. Di Cristina” Hospital ARNAS, Palermo, Italy. Acta Med Mediterr. 2003;19(1):63-66. No prevalence or incidence reported.
Schapira M, Maisin J M, Ghilain J M, et al. Epidemiology of coeliac disease. Acta Gastro-Enterol Belg. 2003;66(3):234-236. Review article.
Schatz D A, Winter W E. Autoimmune polyglandular syndrome II: Clinical syndrome and treatment. Endocrinol Metab Clin North Am. 2002;31(2):339-352. No prevalence or incidence reported. [pmid: 12092454].
Schenker S. Adverse reactions to food. Nutr Bull. 2002;27(2):125-127. No prevalence or incidence reported.
Schlichting J, Leuschner U. Drug therapy of primary biliary diseases: classical and modern strategies. J Cell Mol Med. 2001;5(1):98-115. No prevalence or incidence reported. [pmid: 12067457].
Schmidt E, Schmidt F W. Clinical aspects of gut enzymology. Journal of Clinical Chemistry and Clinical Biochemistry. Zeitschrift Fur Klinische Chemie Und Klinische Biochemie. 1979;17(11):693-704. No prevalence or incidence reported. [pmid: 232715].
Schober Edith, Rami Birgit, Granditsch Gerhard, et al. Coeliac disease in children and adolescents with type 1 diabetes mellitus: to screen or not, to treat or not?. Horm Res. 2002;57(Suppl 1):97-100. No prevalence or incidence reported. [pmid: 11979035].
Scholz S, Albert E. HLA and diseases: involvement of more than one HLA-linked determinant of disease susceptibility. Immunol Rev 1983;7077–88. No prevalence or incidence reported
Schrumpf E, Abdelnoor M, Fausa O, et al. Risk factors in primary sclerosing cholangitis. J Hepatol. 1994;21(6):1061-1066. No prevalence or incidence reported. [pmid: 7699228].
Schuppan D, Ciccocioppo R. Coeliac disease and secondary autoimmunity. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(1):13-15. No prevalence or incidence reported. [pmid: 11926568].
Schuppan D, Esslinger B, Dieterich W. Innate immunity and coeliac disease. Lancet. 2003;362(9377):3-4. No prevalence or incidence reported. [pmid: 12853189].
Schuppan D, Hahn E G. Celiac disease and its link to type 1 diabetes mellitus. Journal of Pediatric Endocrinology & Metabolism - Jpem. 2001;14(Suppl 1):597-605. No prevalence or incidence reported. [pmid: 11393550].
Schuppan D, Hahn E G. IgA anti-tissue transglutaminase: setting the stage for coeliac disease screening. Eur J Gastroenterol Hepatol. 2001;13(6):635-637. No prevalence or incidence reported. [pmid: 11434587].
Schuppan Detlef, Hahn Eckhart G. Biomedicine. Gluten and the gut-lessons for immune regulation. Science. 2002;297(5590):2218-2220. No prevalence or incidence reported. [pmid: 12351776].
Schwartz M K, Sleisenger M H, Pert J H, et al. The effect of a gluten-free diet on fat, nitrogen, and mineral metabolism in patients with sprue. Gastroenterology. 1968;54(4):Suppl 791-Suppl 792. No prevalence or incidence reported. [pmid: 5659824].
Schweizer J J, Oren A, Mearin M L. Cancer in children with celiac disease: a survey of the European Society of Paediatric Gastroenterology, Hepatology and Nutrition. J Pediatr Gastroenterol Nutr. 2001;33(1):97-100. No prevalence or incidence reported. [pmid: 11479418].
Scolapio J S, Fleming C R, Kelly D G, et al. Survival of home parenteral nutrition-treated patients: 20 years of experience at the Mayo Clinic. Mayo Clin Proc. 1999;74(3):217-222. No prevalence or incidence reported. [pmid: 10089988].
Scott B B, Young S, Rajah S M, et al. Proceedings: The incidence of coeliac diseases and HL-A8 in dermatitis herpetiformis. Gut. 1975;16(10):845. No prevalence or incidence reported. [pmid: 1205335].
Scott E M, Gaywood I, Scott B B. Guidelines for osteoporosis in coeliac disease and inflammatory bowel disease. British Society of Gastroenterology. Gut. 2000;46(Suppl 1):1-8. No prevalence or incidence reported. [pmid: 10647595]. [pmcid: 1727766].
Scott E M, Scott B B. A strategy for osteoporosis in gastroenterology. Eur J Gastroenterol Hepatol. 1998;10(8):689-696. No prevalence or incidence reported. [pmid: 9744699].
Scott F W, Rowsell P, Wang G-S, et al. Oral exposure to diabetes-promoting food or immunomodulators in neonates alters gut cytokines and diabetes. Diabetes. 2002;51(1):73-78. No prevalence or incidence reported. [pmid: 11756325].
Scott H W, Law D H, Sandstead H H, et al. Jejunoileal shunt in surgical treatment of morbid obesity. Ann Surg. 1970;171(5):770-782. No prevalence or incidence reported. [pmid: 5445664]. [pmcid: 1396821].
Scott H, Ek J, Havnen J, et al. Serum antibodies to dietary antigens: a prospective study of the diagnostic usefulness in celiac disease of children. J Pediatr Gastroenterol Nutr. 1990;11(2):215-220. No prevalence or incidence reported. [pmid: 2395062].
Scott H, Fausa O, Ek J, et al. Measurements of serum IgA and IgG activities to dietary antigens. A prospective study of the diagnostic usefulness in adult coeliac disease. Scand J Gastroenterol. 1990;25(3):287-292. No prevalence or incidence reported. [pmid: 2320948].
Seah P P, Fry L, Holborow E J, et al. Antireticulin antibody: incidence and diagnostic significance. Gut. 1973;14(4):311-315. No prevalence or incidence reported. [pmid: 4574903]. [pmcid: 1412607].
Sedghizadeh Parish P, Shuler Charles F, Allen Carl M, et al. Celiac disease and recurrent aphthous stomatitis: a report and review of the literature. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2002;94(4):474-478. No prevalence or incidence reported. [pmid: 12374923].
Sela B-A. Homocysteine gets to the brain. Isr Med Assoc J. 2002;4(3):204-206. No prevalence or incidence reported. [pmid: 12489510].
Selby P L, Davies M, Adams J E, et al. Bone loss in celiac disease is related to secondary hyperparathyroidism. Journal of Bone and Mineral Research - the Official Journal of the American Society for Bone and Mineral Research. 1999;14(4):652-657. No prevalence or incidence reported. [pmid: 10234588].
Selby R, Barnard J M, Buehler S K, et al. Tuberculosis associated with HLA--B8, BfS in a Newfoundland community study. Tissue Antigens. 1978;11(5):403-408. No prevalence or incidence reported. [pmid: 694904].
Selby W S, Gallagher N D. Malignancy in a 19-year experience of adult celiac disease. Dig Dis Sci. 1979;24(9):684-688. No prevalence or incidence reported. [pmid: 487922].
Selzer G, Sherman G, Callihan T R, et al. Primary small intestinal lymphomas and alpha-heavy-chain disease. A study of 43 cases from a pathology department in Israel. Isr J Med Sci. 1979;15(2):111-123. No prevalence or incidence reported. [pmid: 112083].
Semrad C E. Bone mass and gastrointestinal disease. Ann N Y Acad Sci 2000;904564–570. No prevalence or incidence reported
Senarath Yapa R S. Coeliac disease in young and old patients. J Clin Exp Gerontol. 1991;13(3):95-102. No prevalence or incidence reported.
Sentongo T A, Rutstein R M, Stettler N, et al. Association between steatorrhea, growth, and immunologic status in children with perinatally acquired HIV infection. Arch Pediatr Adolesc Med. 2001;155(2):149-153. No prevalence or incidence reported. [pmid: 11177089].
Shah A, Mayberry J F, Williams G, et al. Epidemiological survey of coeliac disease and inflammatory bowel disease in first-degree relatives of coeliac patients. Q J Med. 1990;74(275):283-288. Not a relevant screening test. [pmid: 2385735].
Shah V H, Rotterdam H, Kotler D P, et al. All that scallops is not celiac disease. Gastroenterol Int. 2000;51(6):717-720. No prevalence or incidence reported.
Shahbazkhani Bijan, Malekzadeh Reza, Sotoudeh Masoud, et al. High prevalence of coeliac disease in apparently healthy Iranian blood donors. Eur J Gastroenterol Hepatol. 2003;15(5):475-478. Not a relevant screening geography. [pmid: 12702902].
Shaker J L, Brickner R C, Findling J W, et al. Hypocalcemia and skeletal disease as presenting features of celiac disease. Arch Intern Med. 1997;157(9):1013-1016. No prevalence or incidence reported. [pmid: 9140273].
Shaker J L, Magill S B, Lalande B M, et al. Endocrine manifestations of celiac disease. Endocr Pract. 2002;12(2):110-116. No prevalence or incidence reported.
Shaltout A A, Khuffash F A, Hilal A A, et al. Pattern of protracted diarrhoea among children in Kuwait. Ann Trop Paediatr. 1989;9(1):30-32. No prevalence or incidence reported. [pmid: 2471440].
Shamir R, Eliakim R, Lahat N, et al. ELISA of anti-endomysial antibodies in the diagnosis of celiac disease: Comparison with immunofluorescence assay of anti-endomysial antibodies and tissue transglutaminase antibodies. Isr Med Assoc J. 2002;4(8):594-596. No prevalence or incidence reported. [pmid: 12183862].
Shamir R, Levine A, Yalon-Hacohen M, et al. Faecal occult blood in children with coeliac disease. Eur J Pediatr. 2000;159(11):832-834. No prevalence or incidence reported. [pmid: 11079196].
Shamir R, Shoenfeld Y, Blank M, et al. The prevalence of coeliac disease antibodies in patients with the antiphospholipid syndrome. Lupus. 2003;12(5):394-399. No prevalence or incidence reported. [pmid: 12765303].
Shamir R. Advances in celiac disease. Gastroenterol Clin North Am. 2003;32(3):931-947. No prevalence or incidence reported. [pmid: 14562582].
Shamir Raanan, Lerner Aaron, Shinar Eilat, et al. The use of a single serological marker underestimates the prevalence of celiac disease in Israel: a study of blood donors. Am J Gastroenterol. 2002;97(10):2589-2594. Not a relevant screening geography. [pmid: 12385444].
Shanahan F, McKenna R, McCarthy C F, et al. Coeliac disease and diabetes mellitus: A study of 24 patients with HLA typing. Qjm - Monthly Journal of the Association of Physicians. 1982;51(203):329-335. No prevalence or incidence reported.
Shand A G, Ciclitira P J. Celiac disease. Clin Perspect Gastroenterol. 2002;5(5):277-283. No prevalence or incidence reported.
Shaoul R, Marcon M A, Okada Y, et al. Gastric metaplasia: a frequently overlooked feature of duodenal biopsy specimens in untreated celiac disease. J Pediatr Gastroenterol Nutr. 2000;30(4):397-403. No prevalence or incidence reported. [pmid: 10776950].
Sharma B C, Bhasin D K, Makharia G, et al. Diagnostic value of push-type enteroscopy: a report from India. Am J Gastroenterol. 2000;95(1):137-140. No prevalence or incidence reported. [pmid: 10638572].
Sheldon W. Prognosis in early adult life of coeliac children treated with a gluten-free diet. Br Med J. 1969;2(654):401-404. No prevalence or incidence reported. [pmid: 5781486]. [pmcid: 1983338].
Shepherd N A, Blackshaw A J, Hall P A, et al. Malignant lymphoma with eosinophilia of the gastrointestinal tract. Histopathology. 1987;11(2):115-130. No prevalence or incidence reported. [pmid: 3570175].
Sher K S, Fraser R C, Wicks A C, et al. High risk of coeliac disease in Punjabis. Epidemiological study in the south Asian and European populations of Leicestershire. Digestion. 1993;54(3):178-182. Not a relevant screening geography. [pmid: 8359561].
Sher K S, Mayberry J F. Female fertility, obstetric and gynaecological history in coeliac disease. A case control study. Digestion. 1994;55(4):243-246. No prevalence or incidence reported. [pmid: 8063029].
Sher K S, Mayberry J F. Female fertility, obstetric and gynaecological history in coeliac disease: a case control study. Acta Paediatr. 1996;412(Suppl):76-77. No prevalence or incidence reported.
Sherman S L, Iselius L, Ellis A et al. Combined segregation and linkage analysis of coeliac disease. Genetic Epidemiology.Supplement 1986;1283–288. No prevalence or incidence reported
Sherman S L. Genetic analysis workshop IV: summary for coeliac disease. Genetic Epidemiology. Supplement. 1986;1(Suppl):271-276. No prevalence or incidence reported.
Shibahara M, Nanko H, Shimizu M, et al. Dermatitis herpetiformis in Japan: An update. Arch Dermatol. 2002;204(1):37-42. No prevalence or incidence reported.
Shidrawi R G, Ciclitira P J. Celiac disease. Curr Opin Gastroenterol. 1996;12(2):159-163. No prevalence or incidence reported.
Shidrawi R G, Day P, Przemioslo R, et al. In vitro toxicity of gluten peptides in coeliac disease assessed by organ culture. Scand J Gastroenterol. 1995;30(8):758-763. No prevalence or incidence reported. [pmid: 7481543].
Shipman R T, Williams A L, Kay R, et al. A family study of coeliac disease. Aust N Z J Med. 1975;5(3):250-255. Serology screen <1990. [pmid: 1057937].
Shmerling D H, Franckx J. Childhood celiac disease: a long-term analysis of relapses in 91 patients. J Pediatr Gastroenterol Nutr. 1986;5(4):565-569. No prevalence or incidence reported. [pmid: 3735007].
Sibert J R, Morgan R J H, O'Connell H I, et al. Is regional Paediatric Surveillance useful? Experience in Wales. Arch Dis Child. 2001;84(6):486-487. No prevalence or incidence reported. [pmid: 11369563].
Sicherer S H, Mun tilde, Murphy R, et al. Symposium: Pediatric food allergy. Pediatrics. 2003;111(6 III):1591-1594. No prevalence or incidence reported. [pmid: 12777597].
Sicherer S H, Sampson H A. Food hypersensitivity and atopic dermatitis: pathophysiology, epidemiology, diagnosis, and management. J Allergy Clin Immunol. 1999;104(3 Pt 2):S114-S122. No prevalence or incidence reported. [pmid: 10482862].
Signer E, Burgin-Wolff A, Berger R, et al. Antibodies to gliadin as a screening test for coeliac disease. A prospective study. Helv Paediatr Acta. 1979;34(1):41-52. No prevalence or incidence reported. [pmid: 372144].
Signore A, Chianelli M, Annovazzi A, et al. Imaging active lymphocytic infiltration in coeliac disease with iodine-123-interleukin-2 and the response to diet. Eur J Nucl Med. 2000;27(1):18-24. No prevalence or incidence reported. [pmid: 10654142].
Signore A, Picarelli A, Annovazzi A, et al. 123I-Interleukin-2: biochemical characterization and in vivo use for imaging autoimmune diseases. Nucl Med Commun. 2003;24(3):305-316. No prevalence or incidence reported. [pmid: 12612472].
Signore A, Picarelli A, Chianelli M, et al. sup 1sup 2sup 3I-Interleukin-2 scintigraphy: A new approach to assess disease activity in autoimmunity. Journal of Pediatric Endocrinology & Metabolism - Jpem. 1996;9(Suppl 1):139-144. No prevalence or incidence reported. [pmid: 8887165].
Sigurgeirsson B, Agnarsson B A, Lindelof B. Risk of lymphoma in patients with dermatitis herpetiformis. BMJ. 1994;308(6920):13-15. No prevalence or incidence reported. [pmid: 8298344].
Sigurs N, Hattevig G, Kjellman B, et al. Appearance of atopic disease in relation to serum IgE antibodies in children followed up from birth for 4 to 15 years. J Allergy Clin Immunol. 1994;94(4):757-763. No prevalence or incidence reported. [pmid: 7930310].
Silink M. How should we manage celiac disease in childhood diabetes?. Pediatr Diabetes. 2001;2(3):95-97. No prevalence or incidence reported. [pmid: 15016190].
Silton R P, Fernandez-Caldas E, Trudeau W L, et al. Prevalence of specific IgE to the storage mite, Aleuroglyphus ovatus. J Allergy Clin Immunol. 1991;88(4):595-603. No prevalence or incidence reported. [pmid: 1918725].
Silva E M, Fernandes M I, Galvao L C, et al. Human leukocyte antigen class II alleles in white Brazilian patients with celiac disease. J Pediatr Gastroenterol Nutr. 2000;31(4):391-394. No prevalence or incidence reported. [pmid: 11045836].
Sipetic S, Vlajinac H, Kocev N, et al. Family history and risk of type 1 diabetes mellitus. Acta Diabetol. 2002;39(3):111-115. No prevalence or incidence reported. [pmid: 12357294].
Sjoberg K, Lindgren S, Eriksson S. Frequent occurrence of non-specific gliadin antibodies in chronic liver disease. Endomysial but not gliadin antibodies predict coeliac disease in patients with chronic liver disease. Scand J Gastroenterol. 1997;32(11):1162-1167. No prevalence or incidence reported. [pmid: 9399399].
Sjogren A, Floren C H, Nilsson A. Measurements of magnesium in mononuclear cells. Sci Total Environ. 1985;42(12):77-82. No prevalence or incidence reported. [pmid: 4012290].
Skeen M B. Neurologic manifestations of gastrointestinal disease. Neurol Clin. 2002;20(1):195-225. No prevalence or incidence reported. [pmid: 11754307].
Skovbjerg H, Sjostrom H, Noren O B. Coeliac disease - A diagnostic and scientific challenge. Ugeskr Laeg. 2002;164(25):3329-3333. No prevalence or incidence reported. [pmid: 12107945].
Skre H, Berg K. Cerebellar ataxia and total albinism: a kindred suggesting pleitotropism or linkage. Clin Genet. 1974;5(3):196-204. No prevalence or incidence reported. [pmid: 4838888].
Smecuol E, Bai J C, Vazquez H, et al. Gastrointestinal permeability in celiac disease. Gastroenterology. 1997;112(4):1129-1136. No prevalence or incidence reported. [pmid: 9097995].
Smecuol E, Gonzalez D, Mautalen C, et al. Longitudinal study on the effect of treatment on body composition and anthropometry of celiac disease patients. Am J Gastroenterol. 1997;92(4):639-643. No prevalence or incidence reported. [pmid: 9128314].
Smecuol E, Maurino E, Vazquez H, et al. Gynaecological and obstetric disorders in coeliac disease: frequent clinical onset during pregnancy or the puerperium. Eur J Gastroenterol Hepatol. 1996;8(1):63-89. No prevalence or incidence reported. [pmid: 8900911].
Smecuol E, Vazquez H, Sugai E, et al. Sugar tests detect celiac disease among first-degree relatives. Am J Gastroenterol. 1999;94(12):3547-3552. No prevalence or incidence reported. [pmid: 10606317].
Smith L J, Lacaille F, Lepage G, et al. Taurine decreases fecal fatty acid and sterol excretion in cystic fibrosis. A randomized double-blind trial. Am J Dis Child. 1991;145(12):1401-1404. No prevalence or incidence reported. [pmid: 1669669].
Smith R, Phillips A J. Osteoporosis during pregnancy and its management. Scandinavian Journal of Rheumatology.Supplement 1998;10766–67. No prevalence or incidence reported
Smith S E, Littlewood J M. The two-film barium meal in the exclusion of coeliac disease. Clin Radiol. 1977;28(6):629-634. No prevalence or incidence reported. [pmid: 589918].
Snook J A, Dwyer L, Lee-Elliott C, et al. Adult coeliac disease and cigarette smoking. Gut. 1996;39(1):60-62. No prevalence or incidence reported. [pmid: 8881810]. [pmcid: 1383232].
Sokol E M, Brown G M, Frucht H L. Nontropical sprue in siblings with dissimilar, unusual, and severe manifestations. Gastroenterology. 1969;56(1):117-123. No prevalence or incidence reported. [pmid: 5304530].
Sollid L M, Lundin K E. Coeliac disease. An inappropriate immune response. Lancet. 2001;358(Suppl):s13. No prevalence or incidence reported. [pmid: 11784562].
Sollid L M, Markussen G, Ek J, et al. Evidence for a primary association of celiac disease to a particular HLA-DQ alpha/beta heterodimer. J Exp Med. 1989;169(1):345-350. No prevalence or incidence reported. [pmid: 2909659].
Sollid L M, Thorsby E. HLA susceptibility genes in celiac disease: genetic mapping and role in pathogenesis. Gastroenterology. 1993;105(3):910-922. No prevalence or incidence reported. [pmid: 8359659].
Sollid L M, Thorsby E. The primary association of celiac disease to a given HLA-DQ alpha/beta heterodimer explains the divergent HLA-DR associations observed in various Caucasian populations. Tissue Antigens. 1990;36(3):136-137. No prevalence or incidence reported. [pmid: 2278049].
Sollid L, Bruserud O, Gaudernack G, et al. The role of the CD8-positive subset of T cells in proliferative responses to soluble antigens. I. Studies of healthy subjects, type 1 diabetics, and coeliac disease patients. Scand J Immunol. 1986;23(4):461-467. No prevalence or incidence reported. [pmid: 3010444].
Sollid Ludvig M. Coeliac disease: dissecting a complex inflammatory disorder. Nature Reviews. Immunology. 2002;2(9):647-655. No prevalence or incidence reported. [pmid: 12209133].
Somech Raz, Spirer Zvi. Celiac disease: extraintestinal manifestations, associated diseases, and complications. Adv Pediatr 2002; 49191–201. No prevalence or incidence reported
Sonwalkar S A, Holbrook I B, Phillips I, et al. A prospective, comparative study of the para-aminobenzoic acid test and faecal elastase 1 in the assessment of exocrine pancreatic function. Aliment Pharmacol Ther. 2003;17(3):467-471. No prevalence or incidence reported. [pmid: 12562462].
Sood A, Midha V, Sood N, et al. Adult celiac disease in northern India. Indian J Gastroenterol. 2003;22(4):124-126. No prevalence or incidence reported. [pmid: 15030042].
Sorensen H T, Fonager K. Risk estimation of disorders associated with coeliac disease. A 16-year Danish nationwide follow-up study based on hospital discharge data. Implications for screening. Int J Risk Saf Med. 1996;8(2):137-140. No prevalence or incidence reported.
Sorensen H T, Thulstrup A M, Blomqvist P, et al. Risk of primary biliary liver cirrhosis in patients with coeliac disease: Danish and Swedish cohort data. Gut. 1999;44(5):736-738. No prevalence or incidence reported. [pmid: 10205215]. [pmcid: 1727481].
Soresi M, Amplo M, Agliastro R, et al. Screening for autoantibodies to tissue transglutaminase reveals a low prevalence of celiac disease in blood donors with cryptogenic hypertransaminasemia. Digestion. 2001;64(2):87-91. No prevalence or incidence reported. [pmid: 11684821].
Souroujon M, Ashkenazi A, Lupo M, et al. Serum ferritin levels in celiac disease. Am J Clin Pathol. 1982;77(1):82-86. No prevalence or incidence reported. [pmid: 7055099].
Specker B L. The significance of high bone density in children. Eur J Pediatr. 2001;139(4):473-475. No prevalence or incidence reported.
Spergel Jonathan M, Beausoleil Janet L, Mascarenhas Maria, et al. The use of skin prick tests and patch tests to identify causative foods in eosinophilic esophagitis. J Allergy Clin Immunol. 2002;109(2):363-368. No prevalence or incidence reported. [pmid: 11842310].
Spiller Robin C. Postinfectious irritable bowel syndrome. Gastroenterology. 2003;124(6):1662-1671. No prevalence or incidence reported. [pmid: 14724817].
Spiro H M. About this issue. J Clin Gastroenterol. 1995;20(4):271. No prevalence or incidence reported. [pmid: 8648049].
Spurkland A, Ingvarsson G, Falk E S, et al. Dermatitis herpetiformis and celiac disease are both primarily associated with the HLA-DQ (alpha 1*0501, beta 1*02) or the HLA-DQ (alpha 1*03, beta 1*0302) heterodimers. Tissue Antigens. 1997;49(1):29-34. No prevalence or incidence reported. [pmid: 9027962].
Stahlberg M R, Hietanen E. Glutathione and glutathione-metabolizing enzymes in the erythrocytes of healthy children and in children with insulin-dependent diabetes mellitus, juvenile rheumatoid arthritis, coeliac disease and acute lymphoblastic leukaemia. Scand J Clin Lab Invest. 1991;51(2):125-130. No prevalence or incidence reported. [pmid: 2042016].
Stahlberg M R, Savilahti E, Siimes M A. Iron deficiency in coeliac disease is mild and it is detected and corrected by gluten-free diet. Acta Paediatr Scand. 1991;80(2):190-193. No prevalence or incidence reported. [pmid: 2035309].
Stanner S. Is breast best for the heart?. Nutr Bull. 2001;26(3):199-200. No prevalence or incidence reported.
Stazi A V, Mantovani A. A risk factor for female fertility and pregnancy: celiac disease. Gynecological Endocrinology - the Official Journal of the International Society of Gynecological Endocrinology. 2000;14(6):454-463. No prevalence or incidence reported. [pmid: 11228068].
Stazi Maria, Antonietta Cotichini, Rodolfo Patriarca, et al. The Italian Twin Project: from the personal identification number to a national twin registry. Twin Research - the Official Journal of the International Society for Twin Studies. 2002;5(5):382-386. No prevalence or incidence reported. [pmid: 12537863].
Stein E, Shane E. Secondary osteoporosis. Endocrinol Metab Clin North Am. 2003;32(1):115-134. No prevalence or incidence reported. [pmid: 12699295].
Steinfeld C M, Moertel C G, Woolner L B. Diarrhea and medullary carcinoma of the thyroid. Cancer. 1973;31(5):1237-1239. No prevalence or incidence reported. [pmid: 4705162].
Stenhammar L, Ansved P, Jansson G, et al. The incidence of childhood celiac disease in Sweden. J Pediatr Gastroenterol Nutr. 1987;6(5):707-709. Serology screen <1990. [pmid: 3694364].
Stenhammar L, Fallstrom S P, Jansson G, et al. Coeliac disease in children of short stature without gastrointestinal symptoms. Eur J Pediatr. 1986;145(3):185-186. No prevalence or incidence reported. [pmid: 3769972].
Stenhammar L, Johansson C G. The incidence of coeliac disease in children in south-east Sweden. Acta Paediatr Scand. 1981;70(3):379-381. Serology screen <1990. [pmid: 7246129].
Stenhammar L. Transient gastro-intestinal disorders during infancy and early childhood. A follow-up study with special reference to coeliac disease. Acta Paediatr Scand. 1981;70(3):383-387. No prevalence or incidence reported. [pmid: 7246130].
Stern M, Bender S W, Gruttner R, et al. Serum antibodies against gliadin and reticulin in a family study of coeliac disease. Eur J Pediatr. 1980;135(1):31-36. No prevalence or incidence reported. [pmid: 7004874].
Stern M, Teuscher M, Wechmann T. Serological screening for coeliac disease: methodological standards and quality control. Acta Paediatr. 1996;412(Suppl):49-51. No prevalence or incidence reported.
Stern M. Comparative evaluation of serologic tests for celiac disease: A European initiative toward standardization. J Pediatr Gastroenterol Nutr. 2000;31(5):513-519. No prevalence or incidence reported. [pmid: 11144436].
Stevens F M, Egan-Mitchell B, Cryan E, et al. Decreasing incidence of coeliac disease. Arch Dis Child. 1987;62(5):465-468. Serology screen <1990. [pmid: 3606178].
Stevens F M, Hitchcock H T. Farmer's lung disease and coeliac disease: a prospective study. Ir J Med Sci. 1977;146(10):335-339. No prevalence or incidence reported. [pmid: 591277].
Stevens F M, Lloyd R S, Geraghty S M, et al. Schizophrenia and coeliac disease--the nature of the relationship. Psychol Med. 1977;7(2):259-263. No prevalence or incidence reported. [pmid: 877189].
Stevens F M, Lloyd R, Egan-Mitchell B, et al. Proceedings: Antireticulin antibodies in coeliacs and their relatives. Gut. 1973;14(10):829. Not a relevant screening test. [pmid: 4758701].
Stevens F M, Lloyd R, Egan-Mitchell B, et al. Reticulin antibodies in patients with coeliac disease and their relatives. Gut. 1975;16(8):598-602. Serology screen <1990. [pmid: 1102397]. [pmcid: 1411013].
Stevens R F, Meyer S. Fanconi and Glanzmann: The men and their works. Br J Haematol. 2002;119(4):901-904. No prevalence or incidence reported. [pmid: 12472566].
Stewart J. Child coeliacs in adult life. Ir Med J. 1974;67(15):411-414. No prevalence or incidence reported. [pmid: 4412415].
Stocker F, Ammann P, Rossi E. Selective gamma-A-globulin deficiency, with dominant autosomal inheritance in a Swiss family. Arch Dis Child. 1968;43(231):585-588. No prevalence or incidence reported. [pmid: 4177045].
Stockman J A. Clinical facts and curios. Curr Probl Pediatr. 1992;22(9):413-419. No prevalence or incidence reported.
Stokes P L, Asquith P, Cooke W T. Genetics of coeliac disease. Clin Gastroenterol. 1973;2(3):547-556. No prevalence or incidence reported.
Stokes P L, Asquith P, Holmes G K, et al. Inheritance and influence of histocompatibility (HL-A) antigens in adult coeliac disease. Gut. 1973;14(8):627-630. No prevalence or incidence reported. [pmid: 4743492]. [pmcid: 1412749].
Stokes P L, Asquith P, Waterhouse J H, et al. Malignancy in relatives of patients with adult coeliac disease. Gut. 1972;13(10):836-837. No prevalence or incidence reported. [pmid: 5087074]. [pmcid: 1412477].
Stokes P L, Holmes G K, Smits B J. Immunoglobulin levels in families with coeliac disease. Lancet. 1972;2(7777):608. No prevalence or incidence reported. [pmid: 4115790].
Stokes P L, Prior P, Sorahan T M. Malignancy in relatives of patients with coeliac disease. Br J Prev Soc Med. 1976;30(1):17-21. No prevalence or incidence reported. [pmid: 949568].
Storm W. Prevalence and diagnostic significance of gliadin antibodies in children with Down syndrome. Eur J Pediatr. 1990;149(12):833-834. No prevalence or incidence reported. [pmid: 2146127].
Storsrud S, Olsson M, Arvidsson Lenner R, et al. Adult coeliac patients do tolerate large amounts of oats. Eur J Clin Nutr. 2003;57(1):163-169. No prevalence or incidence reported. [pmid: 12548312].
Storsrud Stine, Hulthen Lena R, Lenner Ragnhild A. Beneficial effects of oats in the gluten-free diet of adults with special reference to nutrient status, symptoms and subjective experiences. Br J Nutr. 2003;90(1):101-107. No prevalence or incidence reported. [pmid: 12844381].
Stringer Veysi V T, Puntis J W, Batcup G, et al. Gastroduodenal ulcers in the Helicobacter pylori era. Acta Paediatr. 2000;89(10):1181-1185. No prevalence or incidence reported. [pmid: 11083372].
Strobel S, Brydon W G, Ferguson A. Cellobiose/mannitol sugar permeability test complements biopsy histopathology in clinical investigation of the jejunum. Gut. 1984;25(11):1241-1246. No prevalence or incidence reported. [pmid: 6437913]. [pmcid: 1432305].
Strobel S, Busuttil A, Ferguson A. Human intestinal mucosal mast cells: expanded population in untreated coeliac disease. Gut. 1983;24(3):222-227. No prevalence or incidence reported. [pmid: 6826106]. [pmcid: 1419930].
Strober W. Genetic and anthropologic factors in gluten-sensitive enteropathy. Am J Phys Anthropol. 1983;62(1):119-126. No prevalence or incidence reported. [pmid: 6624897].
Stromberg L. Diagnostic accuracy of the atopy patch test and the skin-prick test for the diagnosis of food allergy in young children with atopic eczema/dermatitis syndrome. Acta Paediatr Int J Paediatr. 2002;91(10):1044-1049. No prevalence or incidence reported.
Suarez R M, Suarez R M. Diseases of the digestive system in Puerto Ricans aged 80 and older. J Am Geriatr Soc. 1967;15(4):383-385. Not a relevant screening geography. [pmid: 6019852].
Sugai E, Srur G, Vazquez H, et al. Steatocrit: a reliable semiquantitative method for detection of steatorrhea. J Clin Gastroenterol. 1994;19(3):206-209. No prevalence or incidence reported. [pmid: 7806830].
Sugai Emilia, Chernavsky Alejandra, Pedreira Silvia, et al. Bone-specific antibodies in sera from patients with celiac disease: characterization and implications in osteoporosis. J Clin Immunol. 2002;22(6):353-362. No prevalence or incidence reported. [pmid: 12462335].
Suharjono. Intestinal biopsy and coeliac disease. Paediatr Indones. 1971;11(3):116-134. No prevalence or incidence reported. [pmid: 5154768].
Suliman G I. Coeliac disease in Sudanese children. Gut. 1978;19(2):121-125. No prevalence or incidence reported. [pmid: 631627]. [pmcid: 1411809].
Sullivan A. Coeliac disease. Nursing Standard (Royal College of Nursing (Great Britain) - 1987) 1999;14(11):48–52. No prevalence or incidence reported
Suman Shivani, Williams Elizabeth J, Thomas Peter W, et al. Is the risk of adult coeliac disease causally related to cigarette exposure?. Eur J Gastroenterol Hepatol. 2003;15(9):995-1000. No prevalence or incidence reported. [pmid: 12923372].
Sumnik Z, Kolouskova S, Cinek O, et al. HLA-DQA1*05-DQB1*0201 positivity predisposes to coeliac disease in Czech diabetic children. Acta Paediatr. 2000;89(12):1426-1430. Not a relevant screening geography. [pmid: 11195230].
Susi M, Holopainen P, Mustalahti K, et al. Candidate gene region 15q26 and genetic susceptibility to coeliac disease in Finnish families. Scand J Gastroenterol. 2001;36(4):372-374. No prevalence or incidence reported. [pmid: 11336161].
Sutton D R, Baird I M, Stewart J S, et al. Gastrointestinal iron losses in atrophic gastritis, postgastrectomy states and adult coeliac disease. Gut. 1971;12(10):869-870. No prevalence or incidence reported. [pmid: 5123303].
Sutton D R, Stewart J S, Baird I M, et al. “Free” iron loss in atrophic gastritis, post-gastrectomy states, and adult coeliac disease. Lancet. 1970;2(7669):387-389. No prevalence or incidence reported. [pmid: 4194692].
Sutton G. Coeliac disease: Testing the New Zealand iceberg. New Zealand J Med Lab Sci. 2000;54(2):46-48. No prevalence or incidence reported.
Svedberg P, Johansson S, Wallander M-A, et al. Extra-intestinal manifestations associated with irritable bowel syndrome: a twin study. Aliment Pharmacol Ther. 2002;16(5):975-983. No prevalence or incidence reported. [pmid: 11966507].
Svejgaard A, Lobitz W C. HL A histocompability antigens and skin diseases. Br J Dermatol. 1974;91(2):237-241. No prevalence or incidence reported. [pmid: 4137712].
Svejgaard A. HLA and disease. Rev Fr Transfus Immuno-Hematol. 1977;20(1):27-30. No prevalence or incidence reported. [pmid: 882795].
Swerdlow A J, Whittaker S, Carpenter L M, et al. Mortality and cancer incidence in patients with dermatitis herpetiformis: a cohort study. Br J Dermatol. 1993;129(2):140-144. No prevalence or incidence reported. [pmid: 7654572].
Swincow G, Chrobot A M, Bala G, et al. Comparative analysis of etiologic factors, frequency and diagnostic approach to malabsorption syndrome in two time periods: 1980-1986 and 1994-1997. Med Sci Monit. 1999;5(5):891-895. No prevalence or incidence reported.
Swinson C M, Levi A J. Is coeliac disease underdiagnosed?. Br Med J. 1980;281(6250):1258-1260. No prevalence or incidence reported. [pmid: 7427659]. [pmcid: 1714677].
Swinson C M, Slavin G, Coles E C, et al. Coeliac disease and malignancy. Lancet. 1983;1(8316):111-115. No prevalence or incidence reported. [pmid: 6129425].
Sylvester F A. Bone abnormalities in gastrointestinal and hepatic disease. Curr Opin Pediatr. 1999;11(5):402-407. No prevalence or incidence reported. [pmid: 10555591].
Szaflarska-Szczepanik A, Adamska I, Swincow G, et al. Occurrence of allergy symptoms in celiac disease children - Preliminary report. Med Sci Monit. 1998;4(6):942-944. No prevalence or incidence reported.
Szaflarska-Szczepanik A, Czerwionka-Szaflarska M. The frequency of occurrence and clinical picture of celiac disease in the parents of children with the disease. Medical Science Monitor - International Medical Journal of Experimental and Clinical Research. 2001;7(5):971-976. Not a relevant screening geography. [pmid: 11535944].
Szaflarska-Szczepanik Anna. Assessment of correlation between the presence of antiendomysial antibodies and small intestine mucosal villous atrophy in the diagnostics of celiac disease. Medical Science Monitor - International Medical Journal of Experimental and Clinical Research. 2002;8(3):Cr185-Cr188. No prevalence or incidence reported. [pmid: 11887033].
Szathmari M, Tulassay T, Arato A, et al. Bone mineral content and density in asymptomatic children with coeliac disease on a gluten-free diet. Eur J Gastroenterol Hepatol. 2001;13(4):419-424. No prevalence or incidence reported. [pmid: 11338073].
Tabrez S, Roberts I M. Malabsorption and malnutrition. Prim Care 2001; 28(3):505–22, V. No prevalence or incidence reported
Taggart D P, Imrie C W. A new pattern of histologic predominance and distribution of malignant diseases of the small intestine. Surg Gynecol Obstet. 1987;165(6):515-518. No prevalence or incidence reported. [pmid: 3686317].
Tai V, Crowe M, O'Keefe S. Celiac disease in older people. J Am Geriatr Soc. 2000;48(12):1690-1696. No prevalence or incidence reported. [pmid: 11129763].
Talstad I, Fretheim B, Myren J, et al. Graded gastrectomy for duodenal ulcer -- a five-year prospective study. Scand J Gastroenterol. 1975;33(Suppl):1-27. No prevalence or incidence reported.
Taminiau J A. Celiac disease. Curr Opin Pediatr. 1996;8(5):483-486. No prevalence or incidence reported. [pmid: 8946129].
Tandon N, Shtauvere-Brameus A, Hagopian W A et al. Prevalence of ICA-12 and other autoantibodies in north Indian patients with early-onset diabetes. Ann N Y Acad Sci 2002;958214–217. No prevalence or incidence reported
Teahon K, Somasundaram S, Smith T, et al. Assessing the site of increased intestinal permeability in coeliac and inflammatory bowel disease. Gut. 1996;38(6):864-869. No prevalence or incidence reported. [pmid: 8984025]. [pmcid: 1383194].
Tedeschi A, Tuccari G, Magazzu G, et al. Immunohistochemical localization of lactoferrin in duodenojejunal mucosa from celiac children. J Pediatr Gastroenterol Nutr. 1987;6(3):328-334. No prevalence or incidence reported. [pmid: 3323437].
Tessier J L, Davies G A L. Giardiasis. Prim Care Update Ob Gyns. 1999;6(1):8-11. No prevalence or incidence reported.
Thain M E, Hamilton J R, Ehrlich R M. Coexistence of diabetes mellitus and celiac disease. Eur J Pediatr. 1974;85(4):527-529. No prevalence or incidence reported.
Thapa B R. Celiac disease in India. Indian J Pediatr. 1999;66(1 Suppl):S16-S20. No prevalence or incidence reported. [pmid: 11132463].
Thimister P W, Hopman W P, Rosenbusch G, et al. Plasma cholecystokinin and gallbladder responses to increasing doses of bombesin in celiac disease. Dig Dis Sci. 1998;43(3):668-672. No prevalence or incidence reported. [pmid: 9539666].
Thirup P. Steatorrhea cannot be excluded where there is a fecal weight below 0.200 kg per day and a high fecal consistency. Scand J Clin Lab Invest. 1998;58(7):577-583. No prevalence or incidence reported. [pmid: 9890341].
Thomas G E, Clain D J. Proceedings: Tropical sprue in Rhodesia. Gut. 1974;15(10):823. No prevalence or incidence reported. [pmid: 4434928].
Thomas P D, Forbes A, Green J, et al. Guidelines for the investigation of chronic diarrhoea, 2nd edition. Gut. 2003;52(Suppl 5):v1-v15. No prevalence or incidence reported. [pmid: 12801941].
Thomason K, West J, Logan R F A, et al. Fracture experience of patients with coeliac disease: a population based survey. Gut. 2003;52(4):518-522. No prevalence or incidence reported. [pmid: 12631662]. [pmcid: 1773600].
Thompson N P, Montgomery S M, Pounder R E, et al. Is measles vaccination a risk factor for inflammatory bowel disease?. Lancet. 1995;345(8957):1071-1074. No prevalence or incidence reported. [pmid: 7715338].
Thompson N P, Montgomery S M, Pounder R E, et al. Is measles vaccination a risk factor for inflammatory bowel disease?. Lancet. 1995;345(8957):1062-10631071. No prevalence or incidence reported. [pmid: 7715338].
Thomson G. HLA disease associations: models for the study of complex human genetic disorders. Crit Rev Clin Lab Sci. 1995;32(2):183-219. No prevalence or incidence reported. [pmid: 7598790].
Thomson G. Investigation of the mode of inheritance of the HLA associated diseases by the method of antigen genotype frequencies among diseased individuals. Tissue Antigens. 1983;21(2):81-104. No prevalence or incidence reported. [pmid: 6857627].
Thornquist H, Jacobsen G S, Dahl L B, et al. Coeliac disease and gluten-free diet: a following-up study of fifteen young adults. Ann Nutr Metab. 1993;37(6):295-301. No prevalence or incidence reported. [pmid: 8109888].
Thorsby E, Lundin K E A, Ronningen K S et al. Molecular and functional aspects of some disease-associated HLA polymorphisms. Genes and Gene Products in the Development of Diabetes Mellitus: Proceedings of the 3rd Nordisk Insulin Symposium ‘genes Ane Gene Products in the Development of Diabetes Mellitus’ Ics866 1989;55–67. No prevalence or incidence reported
Thorsby E, Lundin K E, Ronningen K S, et al. Molecular basis and functional importance of some disease-associated HLA polymorphisms. Tissue Antigens. 1989;34(1):39-49. No prevalence or incidence reported. [pmid: 2617513].
Thorsby E. Invited anniversary review: HLA associated diseases. Hum Immunol. 1997;53(1):1-11. No prevalence or incidence reported. [pmid: 9361969].
Thurley C A, Kwan W C, Freeman H J, et al. T cell receptor gene expression and genotypes in celiac disease. Pathobiology - Journal of Immunopathology, Molecular and Cellular Biology. 1994;62(56):311-318. No prevalence or incidence reported. [pmid: 7598800].
Tighe M R, Ciclitira P J. The gluten-host interaction. Bailliere's Clin Gastroenterol. 1995;9(2):211-230. No prevalence or incidence reported. [pmid: 7549025].
Tighe M R, Hall M A, Ashkenazi A, et al. Celiac disease among Ashkenazi Jews from Israel. A study of the HLA class II alleles and their associations with disease susceptibility. Hum Immunol. 1993;38(4):270-276. No prevalence or incidence reported. [pmid: 8138422].
Tighe M R, Hall M A, Barbado M, et al. HLA class II alleles associated with celiac disease susceptibility in a southern European population. Tissue Antigens. 1992;40(2):90-97. No prevalence or incidence reported. [pmid: 1357780].
Tighe M R, Hall M A, Cardi E, et al. Associations between alleles of the major histocompatibility complex- encoded ABC transporter gene TAP2, HLA class II alleles, and celiac disease susceptibility. Hum Immunol. 1994;39(1):9-16. No prevalence or incidence reported. [pmid: 8181966].
Tighe R, Ciclitira P J. Celiac disease. Curr Opin Gastroenterol. 1995;11(2):112-115. No prevalence or incidence reported.
Tighe R, Ciclitira P J. Molecular biology of coeliac disease. Arch Dis Child. 1995;73(3):189-191. No prevalence or incidence reported. [pmid: 7492152].
Tiwari J L, Betuel H, Gebuhrer L, et al. Genetic epidemiology of coeliac disease. Genet Epidemiol. 1984;1(1):37-42. No prevalence or incidence reported. [pmid: 6336186].
Toffolon E P, Goldfinger S E. Malabsorption following gastrectomy and ileal resection. Surg Clin North Am. 1974;54(3):647-653. No prevalence or incidence reported. [pmid: 4597043].
Tomei E, Marini M, Messineo D, et al. Computed tomography of the small bowel in adult celiac disease: the jejunoileal fold pattern reversal. Eur Radiol. 2000;10(1):119-122. No prevalence or incidence reported. [pmid: 10663727].
Tomkin G H, Mawhinney M, Nevin N C. Isolated absence of IgA with autosomal dominant inheritance. Lancet. 1971;2(7716):124-125. No prevalence or incidence reported. [pmid: 4104460].
Torinsson Naluai A, Nilsson S, Samuelsson L, et al. The CTLA4/CD28 gene region on chromosome 2q33 confers susceptibility to celiac disease in a way possibly distinct from that of type 1 diabetes and other chronic inflammatory disorders. Tissue Antigens. 2000;56(4):350-355. No prevalence or incidence reported. [pmid: 11098935].
Toskes P P, Dawson W, Curington C, et al. Non-diabetic retinal abnormalities in chronic pancreatitis. N Engl J Med. 1979;300(17):942-946. No prevalence or incidence reported. [pmid: 431561].
Tovey F I, Godfrey J E, Lewin M R. A gastrectomy population: 25–30 years on. Postgrad Med J. 1990;66(776):450-456. No prevalence or incidence reported. [pmid: 2216995].
Trabace S, Giunta A, Rosso M, et al. HLA-ABC and DR antigens in celiac disease. A study in a pediatric Italian population. Vox Sang. 1984;46(2):102-106. No prevalence or incidence reported. [pmid: 6422636].
Tran T M, Van den, Neucker A, et al. Effects of a proton-pump inhibitor in cystic fibrosis. Acta Paediatr. 1998;87(5):553-558. No prevalence or incidence reported. [pmid: 9641739].
Trejdosiewicz L K, Calabrese A, Smart C J, et al. Gamma delta T cell receptor-positive cells of the human gastrointestinal mucosa: occurrence and V region gene expression in Heliobacter pylori-associated gastritis, coeliac disease and inflammatory bowel disease. Clin Exp Immunol. 1991;84(3):440-444. No prevalence or incidence reported. [pmid: 1828397]. [pmcid: 1535443].
Trevisiol C, Ventura A, Baldas V, et al. A reliable screening procedure for coeliac disease in clinical practice. Scand J Gastroenterol. 2002;37(6):679-684. Not a relevant screening group. [pmid: 12126246].
Triolo G, Accardo-Palumbo A, Dieli F, et al. Humoral and cell mediated immune response to cow's milk proteins in Behcet's disease. Ann Rheum Dis. 2002;61(5):459-462. No prevalence or incidence reported. [pmid: 11959773]. [pmcid: 1754076].
Tripp E J, MacKay E H. Silver staining of bone prior to decalcification for quantitative determination of osteoid in sections. Stain Technol. 1972;47(3):129-136. No prevalence or incidence reported. [pmid: 4111887].
Troncone R, Greco L, Auricchio S. Gluten-sensitive enteropathy. Pediatr Clin North Am. 1996;43(2):355-373. No prevalence or incidence reported. [pmid: 8614605].
Troncone R, Greco L, Auricchio S. The controversial epidemiology of coeliac disease. Acta Paediatr. 2000;89(2):140-141. No prevalence or incidence reported. [pmid: 10709880].
Troncone R, Greco L, Mayer M, et al. In siblings of celiac children, rectal gluten challenge reveals gluten sensitization not restricted to celiac HLA. Gastroenterology. 1996;111(2):318-324. No prevalence or incidence reported. [pmid: 8690196].
Troncone R, Mayer M, Spagnuolo F, et al. Endomysial antibodies as unreliable markers for slight dietary transgressions in adolescents with celiac disease. J Pediatr Gastroenterol Nutr. 1995;21(1):69-72. No prevalence or incidence reported. [pmid: 8576818].
Troncone R, Mazzarella G, Leone N, et al. Gliadin activates mucosal cell mediated immunity in cultured rectal mucosa from coeliac patients and a subset of their siblings. Gut. 1998;43(4):484-489. No prevalence or incidence reported. [pmid: 9824574]. [pmcid: 1727290].
Troncone Riccardo, Franzese Adriana, Mazzarella Giuseppe, et al. Gluten sensitivity in a subset of children with insulin dependent diabetes mellitus. Am J Gastroenterol. 2003;98(3):590-595. No prevalence or incidence reported. [pmid: 12650792].
Tumer L, Hasanoglu A, Aybay C. Endomysium antibodies in the diagnosis of celiac disease in short-statured children with no gastrointestinal symptoms. Pediatrics International - Official Journal of the Japan Pediatric Society. 2001;43(1):71-73. No prevalence or incidence reported. [pmid: 11208004].
Turner J M, Lawrence S, Fellows I W, et al. [14C]-triolein absorption: a useful test in the diagnosis of malabsorption. Gut. 1987;28(6):694-700. No prevalence or incidence reported. [pmid: 3623216]. [pmcid: 1433043].
Turowski G, Ke cedil. Soluble HLA class I antigens as a familial genetic background in coeliac disease. Cent-Eur J Immunol. 2001;26(1):28-30. No prevalence or incidence reported.
Tursi A, Brandimarte G, Giorgetti G, et al. Low prevalence of antigliadin and anti-endomysium antibodies in subclinical/silent celiac disease. Am J Gastroenterol. 2001;96(5):1507-1510. No prevalence or incidence reported. [pmid: 11374690].
Tursi A, Brandimarte G, Giorgetti G M. Sorbitol H2-breath test versus anti-endomysium antibodies for the diagnosis of subclinical/silent coeliac disease. Scand J Gastroenterol. 2001;36(11):1170-1172. No prevalence or incidence reported. [pmid: 11686216].
Tursi A, Giorgetti G, Brandimarte G, et al. Prevalence and clinical presentation of subclinical/silent celiac disease in adults: an analysis on a 12-year observation. Hepatogastroenterology. 2001;48(38):462-464. No prevalence or incidence reported. [pmid: 11379333].
Tursi Antonio, Brandimarte Giovanni, Giorgetti Gian, et al. Prevalence of antitissue transglutaminase antibodies in different degrees of intestinal damage in celiac disease. J Clin Gastroenterol. 2003;36(3):219-221. No prevalence or incidence reported. [pmid: 12590232].
Tursi Antonio, Brandimarte Giovanni, Giorgetti GianMarco. High prevalence of small intestinal bacterial overgrowth in celiac patients with persistence of gastrointestinal symptoms after gluten withdrawal. Am J Gastroenterol. 2003;98(4):839-843. No prevalence or incidence reported. [pmid: 12738465].
Tursi Antonio, Brandimarte Giovanni. The symptomatic and histologic response to a gluten-free diet in patients with borderline enteropathy. J Clin Gastroenterol. 2003;36(1):13-17. No prevalence or incidence reported. [pmid: 12488700].
Tuysuz B, Dursun A, Kutlu T, et al. HLA-DQ alleles in patients with celiac disease in Turkey. Tissue Antigens. 2001;57(6):540-542. No prevalence or incidence reported. [pmid: 11556984].
Uibo O, Maaroos H I. Hospital screening of coeliac disease in Estonian children by anti-gliadin antibodies of IgA class. Acta Paediatr. 1993;82(3):233-234. No prevalence or incidence reported. [pmid: 8495074].
Uibo O, Metskula K, Kukk T, et al. Results of coeliac disease screening in Estonia in 1990-1994. Acta Paediatr. 1996;412(Suppl):39-41. Not a relevant screening geography.
Uibo O, Uibo R, Kleimola V, et al. Serum IgA anti-gliadin antibodies in an adult population sample. High prevalence without celiac disease. Dig Dis Sci. 1993;38(11):2034-2037. Not a relevant screening geography. [pmid: 8223078].
Uibo O. Childhood celiac disease in Estonia: efficacy of the IgA-class antigliadin antibody test in the search for new cases. J Pediatr Gastroenterol Nutr. 1994;18(1):53-55. Not a relevant screening geography. [pmid: 8126618].
Uibo R, Sullivan E P, Uibo O, et al. Comparison of the prevalence of glutamic acid decarboxylase (GAD65) and gliadin antibodies (AGA) in a randomly selected adult estonian population. Hormone and Metabolic Research.Hormon- Und Stoffwechselforschung. Hormones Et Metabolisme. 2001;33(9):564-567. No prevalence or incidence reported. [pmid: 11561218].
Uil J J, van Elburg R M, Janssens P M, et al. Sensitivity of a hyperosmolar or “low”-osmolar test solution for sugar absorption in recognizing small intestinal mucosal damage in coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2000;32(3):195-200. No prevalence or incidence reported. [pmid: 10975768].
Uil J J, van Elburg R M, Mulder C J, et al. The value of the D-xylose test compared with the differential sugar absorption test in recognizing coeliac disease. Neth J Med. 1996;49(2):68-72. No prevalence or incidence reported. [pmid: 8824107].
Uil J J, van Elburg R M, van Overbeek F M, et al. Follow-up of treated coeliac patients: sugar absorption test and intestinal biopsies compared. Eur J Gastroenterol Hepatol. 1996;8(3):219-223. No prevalence or incidence reported. [pmid: 8724020].
umnik Z, Kolous caron, Cinek O, et al. HLA - DQA1*05-DQB1*0201 positivity predisposes to coeliac disease in Czech diabetic children. Acta Paediatr Int J Paediatr. 2000;89(12):1426-1430. No prevalence or incidence reported.
Ung K A, Kilander A F, Lindgren A, et al. Impact of bile acid malabsorption on steatorrhoea and symptoms in patients with chronic diarrhoea. Eur J Gastroenterol Hepatol. 2000;12(5):541-547. No prevalence or incidence reported. [pmid: 10833098].
Unsworth D J, Brown D L. Serological screening suggests that adult coeliac disease is underdiagnosed in the UK and increases the incidence by up to 12%. Gut. 1994;35(1):61-64. Not a relevant screening test. [pmid: 8307451]. [pmcid: 1374633].
Usai P, Bassotti G, Satta P, et al. Oesophageal motility in adult coeliac disease. Neurogastroenterol Motil. 1995;7(4):239-244. No prevalence or incidence reported. [pmid: 8574913].
Usai P, Boi M F, Piga M, et al. Adult celiac disease is frequently associated with sacroiliitis. Dig Dis Sci. 1995;40(9):1906-1908. No prevalence or incidence reported. [pmid: 7555441].
Usai P, Minerba L, Marini B, et al. Case control study on health-related quality of life in adult coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(8):547-552. No prevalence or incidence reported. [pmid: 12502210].
Ussher R, Yeong M L, Stace N. Coeliac disease: incidence and prevalence in Wellington 1985-92. N Z Med J. 1994;107(978):195-197. Not a relevant screening geography. [pmid: 8196863].
Vader Willemijn, Kooy Yvonne, Van Veelen, et al. The gluten response in children with celiac disease is directed toward multiple gliadin and glutenin peptides. Gastroenterology. 2002;122(7):1729-1737. No prevalence or incidence reported. [pmid: 12055577].
Vahedi Kouroche, Mascart Francoise, Mary Jean, et al. Reliability of antitransglutaminase antibodies as predictors of gluten-free diet compliance in adult celiac disease. Am J Gastroenterol. 2003;98(5):1079-1087. No prevalence or incidence reported. [pmid: 12809831].
Vaknin-Dembinsky A, Eliakim R, Steiner I. Neurological deficits in patients with celiac disease. Arch Neurol. 2002;59(4):647-648. No prevalence or incidence reported. [pmid: 11939904].
Valdimarsson T, Lofman O, Toss G, et al. Reversal of osteopenia with diet in adult coeliac disease. Gut. 1996;38(3):322-327. No prevalence or incidence reported. [pmid: 8675082]. [pmcid: 1383058].
Valdimarsson T, Toss G, Lofman O, et al. Three years' follow-up of bone density in adult coeliac disease: significance of secondary hyperparathyroidism. Scand J Gastroenterol. 2000;35(3):274-280. No prevalence or incidence reported. [pmid: 10766321].
Valdimarsson T, Toss G, Ross I, et al. Bone mineral density in coeliac disease. Scand J Gastroenterol. 1994;29(5):457-461. No prevalence or incidence reported. [pmid: 8036462].
Valentine R J, Martin J D, Myers S I, et al. Asymptomatic celiac and superior mesenteric artery stenoses are more prevalent among patients with unsuspected renal artery stenoses. Journal of Vascular Surgery - Official Publication, the Society for Vascular Surgery and International Society for Cardiovascular Surgery, North American Chapter. 1991;14(2):195-199. No prevalence or incidence reported. [pmid: 1908908].
Valentini R A, Andreani M L, Corazza G R, et al. IgA endomysium antibody: a valuable tool in the screening of coeliac disease but not its follow-up. Ital J Gastroenterol. 1994;26(6):279-282. No prevalence or incidence reported. [pmid: 7949263].
Valentino R, Savastano S, Tommaselli A P, et al. Prevalence of coeliac disease in patients with thyroid autoimmunity. Horm Res. 1999;51(3):124-127. No prevalence or incidence reported. [pmid: 10461017].
Valentino Rossella, Savastano Silvia, Maglio Maria, et al. Markers of potential coeliac disease in patients with Hashimoto's thyroiditis. Eur J Endocrinol. 2002;146(4):479-483. No prevalence or incidence reported. [pmid: 11916614].
Valleta E A, Mastella G. Incidence of celiac disease in a cystic fibrosis population. Acta Paediatr Scand. 1989;78(5):784-785. No prevalence or incidence reported. [pmid: 2596287].
Valletta E A, Trevisiol D, Mastella G. IgA anti-gliadin antibodies in the monitoring of gluten challenge in celiac disease. J Pediatr Gastroenterol Nutr. 1990;10(2):169-173. No prevalence or incidence reported. [pmid: 2303968].
Valman H B. Proceedings: Diet and growth after resection of ileum in childhood. Gut. 1974;15(10):822. No prevalence or incidence reported. [pmid: 4434924]. [pmcid: 1412981].
van Belzen M J, Mulder C J, Pearson P L, et al. The tissue transglutaminase gene is not a primary factor predisposing to celiac disease. Am J Gastroenterol. 2001;96(12):3337-3340. No prevalence or incidence reported. [pmid: 11774946].
Van Cutsem E, Vantrappen G. Epidemiology and clinical aspects of esophageal cancer. J Belge Radiol. 1991;74(5):365-368. No prevalence or incidence reported. [pmid: 1665845].
van den, Boom S A, Kimber A C, et al. Weaning practices in children up to 19 months of age in Madrid. Acta Paediatr. 1995;84(8):853-858. No prevalence or incidence reported. [pmid: 7488805].
van den, Bosch H C, Tham R T, et al. Celiac disease: small-bowel enteroclysis findings in adult patients treated with a gluten-free diet. Radiology. 1996;201(3):803-808. No prevalence or incidence reported. [pmid: 8939235].
Van den, Neucker A, Pestel N, et al. Clinical use of acid steatocrit. Acta Paediatr. 1997;86(5):466-469. No prevalence or incidence reported. [pmid: 9183483].
Van der, Vliet H J J, Von Blomberg B M E, et al. Circulating Valpha24SUP+ Vbeta11SUP+ NKT cell numbers are decreased in a wide variety of diseases that are characterized by autoreactive tissue damage. Clin Immunol. 2001;100(2):144-148. No prevalence or incidence reported. [pmid: 11465942].
van Elburg R M, Uil J J, Mulder C J, et al. Intestinal permeability in patients with coeliac disease and relatives of patients with coeliac disease. Gut. 1993;34(3):354-357. No prevalence or incidence reported. [pmid: 8472983]. [pmcid: 1374141].
van Overbeek F M, Uil-Dieterman I G, Mol I W, et al. The daily gluten intake in relatives of patients with coeliac disease compared with that of the general Dutch population. Eur J Gastroenterol Hepatol. 1997;9(11):1097-1099. No prevalence or incidence reported. [pmid: 9431901].
van Stirum J, Baerlocher K, Fanconi A, et al. The incidence of coeliac disease in children in Switzerland. Helv Paediatr Acta. 1982;37(5):421-430. Serology screen <1990. [pmid: 7161114].
Van Wouwe J P. Clinical and laboratory diagnosis of acrodermatitis enteropathica. Eur J Pediatr. 1989;149(1):2-8. No prevalence or incidence reported. [pmid: 2691254].
Vancikova Z, Chlumecky V, Sokol D, et al. The serologic screening for celiac disease in the general population (blood donors) and in some high-risk groups of adults (patients with autoimmune diseases, osteoporosis and infertility) in the Czech republic. Folia Microbiol (Praha). 2002;47(6):753-758. Not a relevant screening geography. [pmid: 12630332].
Vanelli M, de Fanti A, Adinolfi B, et al. Clinical data regarding the growth of diabetic children. Horm Res. 1992;37(Suppl 3):65-69. No prevalence or incidence reported. [pmid: 1427645].
Varkonyi A, Boda M, Endreffy E et al. Coeliac disease: always something to discover. Scandinavian Journal of Gastroenterology.Supplement 1998;228122–129. No prevalence or incidence reported
Varma S, Malhotra P, Kochhar R, et al. Celiac disease presenting as iron-deficiency anemia in northern India. Indian Journal of Gastroenterology - Official Journal of the Indian Society of Gastroenterology. 2001;20(6):234-236. Not a relevant screening geography. [pmid: 11817777].
Vartdal F, Johansen B H, Friede T, et al. The peptide binding motif of the disease associated HLA-DQ (alpha 1* 0501, beta 1* 0201) molecule. Eur J Immunol. 1996;26(11):2764-2772. No prevalence or incidence reported. [pmid: 8921967].
Vasquez H, Mazure R, Gonzalez D, et al. Risk of fractures in celiac disease patients: a cross-sectional, case-control study. Am J Gastroenterol. 2000;95(1):183-189. No prevalence or incidence reported. [pmid: 10638580].
Vazquez H, Cabanne A, Sugai E, et al. Serological markers identify histologically latent coeliac disease among first-degree relatives. Eur J Gastroenterol Hepatol. 1996;8(1):15-21. Not a relevant screening geography. [pmid: 8900904].
Vazquez H, Smecuol E, Flores D, et al. Relation between cigarette smoking and celiac disease: evidence from a case-control study. Am J Gastroenterol. 2001;96(3):798-802. No prevalence or incidence reported. [pmid: 11280554].
Vazquez H, Sugai E, Pedreira S, et al. Screening for asymptomatic celiac sprue in families. J Clin Gastroenterol. 1995;21(2):130-133. No prevalence or incidence reported. [pmid: 8583078].
Vecchi M, Bianchi M B, Sinico R A, et al. Antibodies to neutrophil cytoplasm in Italian patients with ulcerative colitis: sensitivity, specificity and recognition of putative antigens. Digestion. 1994;55(1):34-39. No prevalence or incidence reported. [pmid: 8112495].
Vecchi M, Folli C, Donato M F, et al. High rate of positive anti-tissue transglutaminase antibodies in chronic liver disease. Role of liver decompensation and of the antigen source. Scand J Gastroenterol. 2003;38(1):50-54. No prevalence or incidence reported. [pmid: 12608464].
Veitch A M, Kelly P, Zulu I S, et al. Tropical enteropathy: a T-cell-mediated crypt hyperplastic enteropathy. Eur J Gastroenterol Hepatol. 2001;13(10):1175-1181. No prevalence or incidence reported. [pmid: 11711773].
Velluzzi F, Caradonna A, Boy M F, et al. Thyroid and celiac disease: clinical, serological, and echographic study. Am J Gastroenterol. 1998;93(6):976-979. No prevalence or incidence reported. [pmid: 9647032].
Ventura A, Magazzu G, Greco L. Duration of exposure to gluten and risk for autoimmune disorders in patients with celiac disease. SIGEP Study Group for Autoimmune Disorders in Celiac Disease. Gastroenterology. 1999;117(2):297-303. No prevalence or incidence reported. [pmid: 10419909].
Ventura A, Neri E, Ughi C, et al. Gluten-dependent diabetes-related and thyroid-related autoantibodies in patients with celiac disease. Eur J Pediatr. 2000;137(2):263-265. No prevalence or incidence reported.
Venturini I, Cosenza R, Miglioli L, et al. Adult celiac disease and primary sclerosing cholangitis: two case reports. Hepatogastroenterology. 1998;45(24):2344-2347. No prevalence or incidence reported. [pmid: 9951920].
Verge C F, Howard N J, Rowley M J, et al. Anti-glutamate decarboxylase and other antibodies at the onset of childhood IDDM: a population-based study. Diabetologia. 1994;37(11):1113-1120. No prevalence or incidence reported. [pmid: 7867883].
Verkarre V, Asnafi V, Lecomte T, et al. Refractory coeliac sprue is a diffuse gastrointestinal disease. Gut. 2003;52(2):205-211. No prevalence or incidence reported. [pmid: 12524401]. [pmcid: 1774980].
Verkasalo M, Kuitunen P, Leisti S, et al. Growth failure from symptomless celiac disease. A study of 14 patients. Helv Paediatr Acta. 1978;33(6):489-495. No prevalence or incidence reported. [pmid: 216652].
Verkasalo M, Kuitunen P, Savilahti E, et al. Changing pattern of cow's milk intolerance. An analysis of the occurrence and clinical course in the 60s and mid-70s. Acta Paediatr Scand. 1981;70(3):289-295. No prevalence or incidence reported. [pmid: 7195640].
Vermeer B J, Lindeman J, Harst-Oostveen C J, et al. The immunoglobulin-bearing cells in the lamina propria and the clinical response to a gluten-free diet in dermatitis herpetiformis. Archives for Dermatological Research. Archiv Fur Dermatologische Forschung. 1977;258(3):223-230. No prevalence or incidence reported.
Vestergaard Peter, Mosekilde Leif. Fracture risk in patients with celiac Disease, Crohn's disease, and ulcerative colitis: a nationwide follow-up study of 16,416 patients in Denmark. Am J Epidemiol. 2002;156(1):1-10. No prevalence or incidence reported. [pmid: 12076883].
Vestergaard Peter. Bone loss associated with gastrointestinal disease: prevalence and pathogenesis. Eur J Gastroenterol Hepatol. 2003;15(8):851-856. No prevalence or incidence reported. [pmid: 12867793].
Veyrieres M, Baillet P, Hay J M, et al. Factors influencing long-term survival in 100 cases of small intestine primary adenocarcinoma. Am J Surg. 1997;173(3):237-239. No prevalence or incidence reported. [pmid: 9124635].
Visakorpi J K, Kuitunen P, Savilahti E. Frequency and nature of relapses in children suffering from the malabsorption syndrome with gluten intolerance. Acta Paediatr Scand. 1970;59(5):481-486. No prevalence or incidence reported. [pmid: 5455517].
Vissers M, Doekes G, Heederik D. Exposure to wheat allergen and fungal alpha-amylase in the homes of bakers. Clinical and Experimental Allergy - Journal of the British Society for Allergy and Clinical Immunology. 2001;31(10):1577-1582. No prevalence or incidence reported. [pmid: 11678858].
Viteri F E, Schneider R E. Gastrointestinal alterations in protein-calorie malnutrition. Med Clin North Am. 1974;58(6):1487-1505. No prevalence or incidence reported. [pmid: 4214971].
Vivas Santiago, Ruiz de, Morales Jose M, et al. Human recombinant anti-transglutaminase antibody testing is useful in the diagnosis of silent coeliac disease in a selected group of at-risk patients. Eur J Gastroenterol Hepatol. 2003;15(5):479-483. No prevalence or incidence reported. [pmid: 12702903].
Vjero K, Martucci S, Alvisi C, et al. Defining a proper setting for endoscopy in coeliac disease. Eur J Gastroenterol Hepatol. 2003;15(6):675-678. No prevalence or incidence reported. [pmid: 12840680].
Vlissides D N, Venulet A, Jenner F A. A double-blind gluten-free/gluten-load controlled trial in a secure ward population. Br J Psychiatry 1986;148447–452. No prevalence or incidence reported
Vogelsang H, Oberhuber G, Wyatt J. Lymphocytic gastritis and gastric permeability in patients with celiac disease. Gastroenterology. 1996;111(1):73-77. No prevalence or incidence reported. [pmid: 8698227].
Vogelsang H, Schwarzenhofer M, Granditsch G, et al. In vitro production of endomysial antibodies in cultured duodenal mucosa from patients with celiac disease. Am J Gastroenterol. 1999;94(4):1057-1061. No prevalence or incidence reported. [pmid: 10201483].
Vogelsang H, Schwarzenhofer M, Oberhuber G. Changes in gastrointestinal permeability in celiac disease. Dig Dis. 1998;16(6):333-336. No prevalence or incidence reported. [pmid: 10207219].
Vogelsang H, Schwarzenhofer M, Steiner B, et al. In vivo and in vitro permeability in coeliac disease. Aliment Pharmacol Ther. 2001;15(9):1417-1425. No prevalence or incidence reported. [pmid: 11552914].
Vogelsang H, Suk E K, Janisiw M, et al. Calcaneal ultrasound attenuation and vitamin-D-receptor genotypes in celiac disease. Scand J Gastroenterol. 2000;35(2):172-176. No prevalence or incidence reported. [pmid: 10720115].
Vogelsang H, Wyatt J, Penner E, et al. Screening for celiac disease in first-degree relatives of patients with celiac disease by lactulose/mannitol test. Am J Gastroenterol. 1995;90(10):1838-1842. Not a relevant screening test. [pmid: 7572905].
Vogelsang H. The changing features of celiac disease. Preface. Dig Dis. 1998;16(6):328-329. No prevalence or incidence reported. [pmid: 10357615].
Vogelsang Harald, Panzer Simon, Mayr Wolfgang R, et al. Distribution of HLA class I alleles differs in celiac disease patients according to age of onset. Dig Dis Sci. 2003;48(3):611-614. No prevalence or incidence reported. [pmid: 12757179].
Volta U, Bonazzi C, Baldoni A M, et al. Clinical presentation of adult coeliac disease. Ann Med Interne (Paris). 1988;139(2):123-124. No prevalence or incidence reported. [pmid: 3395054].
Volta U, Bonazzi C, Pisi E, et al. Antigliadin and antireticulin antibodies in coeliac disease and at onset of diabetes in children. Lancet. 1987;2(8566):1034-1035. No prevalence or incidence reported. [pmid: 2889951].
Volta U, De Franceschi L, Lari F, et al. Coeliac disease hidden by cryptogenic hypertransaminasaemia. Lancet. 1998;352(9121):26-29. No prevalence or incidence reported. [pmid: 9800742].
Volta U, De Franceschi L, Molinaro N, et al. Frequency and significance of anti-gliadin and anti-endomysial antibodies in autoimmune hepatitis. Dig Dis Sci. 1998;43(10):2190-2195. No prevalence or incidence reported. [pmid: 9790453].
Volta U, De Franceschi L, Molinaro N, et al. Organ-specific autoantibodies in coeliac disease: do they represent an epiphenomenon or the expression of associated autoimmune disorders?. Ital J Gastroenterol Hepatol. 1997;29(1):18-21. No prevalence or incidence reported. [pmid: 9265573].
Volta U, De Giorgio R, Petrolini N, et al. Clinical findings and anti-neuronal antibodies in coeliac disease with neurological disorders. Scand J Gastroenterol. 2002;37(11):1276-1281. No prevalence or incidence reported. [pmid: 12465725].
Volta U, Granito A, De Franceschi L, et al. Anti tissue transglutaminase antibodies as predictors of silent coeliac disease in patients with hypertransaminasaemia of unknown origin. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2001;33(5):420-425. No prevalence or incidence reported. [pmid: 11529654].
Volta U, Lenzi M, Lazzari R, et al. Antibodies to gliadin detected by immunofluorescence and a micro-ELISA method: markers of active childhood and adult coeliac disease. Gut. 1985;26(7):667-671. No prevalence or incidence reported. [pmid: 3894169]. [pmcid: 1432992].
Volta U, Molinaro N, De Franceschi L, et al. Human umbilical cord as substrate for IgA antiendomysial antibodies allows large scale screening for celiac sprue. J Clin Gastroenterol. 1996;23(1):18-20. Not a relevant screening group. [pmid: 8835893].
Volta U, Molinaro N, De Franceschi L, et al. IgA anti-endomysial antibodies on human umbilical cord tissue for celiac disease screening. Save both money and monkeys. Dig Dis Sci. 1995;40(9):1902-1905. No prevalence or incidence reported. [pmid: 7555440].
Volta U, Ravaglia G, Granito A, et al. Coeliac disease in patients with autoimmune thyroiditis. Digestion. 2001;64(1):61-65. No prevalence or incidence reported. [pmid: 11549838].
Volta Umberto, Rodrigo Luis, Granito Alessandro, et al. Celiac disease in autoimmune cholestatic liver disorders. Am J Gastroenterol. 2002;97(10):2609-2613. No prevalence or incidence reported. [pmid: 12385447].
Von Muhlendahl K E, Herkenhoff H. Long-term course of neonatal diabetes. N Engl J Med. 1995;333(11):704-708. No prevalence or incidence reported. [pmid: 7637748].
von Tirpitz, Christian Reinshagen, Max. Management of osteoporosis in patients with gastrointestinal diseases. Eur J Gastroenterol Hepatol. 2003;15(8):869-876. No prevalence or incidence reported. [pmid: 12867796].
Wahab P J, Hopman W P, Jansen J B. Basal and fat-stimulated plasma peptide YY levels in celiac disease. Dig Dis Sci. 2001;46(11):2504-2509. No prevalence or incidence reported. [pmid: 11713961].
Wahab P J, Meijer J W R, Goerres M S et al. Coeliac disease: changing views on gluten-sensitive enteropathy. Scandinavian Journal of Gastroenterology.Supplement 2002;(236):60–65. No prevalence or incidence reported
Wahab Peter J, Meijer Jos W R, Dumitra Daniela, et al. Coeliac disease: more than villous atrophy. Rom J Gastroenterol. 2002;11(2):121-127. No prevalence or incidence reported. [pmid: 12145668].
Wahab Peter J, Meijer Jos W R, Mulder Chris J J. Histologic follow-up of people with celiac disease on a gluten-free diet: slow and incomplete recovery. Am J Clin Pathol. 2002;118(3):459-463. No prevalence or incidence reported. [pmid: 12219789].
Walker W A. Immunology: Editorial overview. Curr Opin Gastroenterol. 1991;7(3):418-420. No prevalence or incidence reported.
Walker-Smith J A, Grigor W. Coeliac disease in a diabetic child. Lancet. 1969;1(7603):1021. No prevalence or incidence reported. [pmid: 4185626].
Walker-Smith J A, Reye R D. Small intestinal morphology in aboriginal children. Aust N Z J Med. 1971;1(4):377-384. No prevalence or incidence reported. [pmid: 5292994].
Walker-Smith J A, Talley N A. Coeliac disease and dermatitis herpetiformis. Med J Aust. 1973;1(1):10-12. No prevalence or incidence reported. [pmid: 4686433].
Walker-Smith J A, Vines R, Grigor W. Coeliac disease and diabetes. Lancet. 1969;2(7621):650. No prevalence or incidence reported. [pmid: 4185626].
Walker-Smith J A. Celiac disease and Down syndrome. Eur J Pediatr. 2000;137(6):743-744. No prevalence or incidence reported.
Walker-Smith J A. Coeliac disease in children of Asian immigrants. Lancet. 1973;1(7800):428. No prevalence or incidence reported. [pmid: 4119738].
Walker-Smith J A. Diabetes and coeliac disease. Lancet. 1969;2(7634):1366. No prevalence or incidence reported. [pmid: 4188128].
Walmsley R S, Ibbotson J P, Chahal H, et al. Antibodies against Mycobacterium paratuberculosis in Crohn's disease. Qjm - Monthly Journal of the Association of Physicians. 1996;89(3):217-221. No prevalence or incidence reported. [pmid: 8731566].
Walsh C H, Cooper B T, Wright A D, et al. Diabetes mellitus and coeliac disease: a clinical study. Q J Med. 1978;47(185):89-100. No prevalence or incidence reported. [pmid: 674552].
Walsh D. Coeliac disease and schizophrenia. Br Med J. 1973;2(5860):242. No prevalence or incidence reported. [pmid: 4733248].
Walsh S V, Egan L J, Connolly C E, et al. Enteropathy-associated T-cell lymphoma in the West of Ireland: low-frequency of Epstein-Barr virus in these tumors. Modern Pathology - an Official Journal of the United States and Canadian Academy of Pathology, Inc. 1995;8(7):753-757. No prevalence or incidence reported. [pmid: 8539233].
Walters J R F, Banks L M, Butcher G P, et al. Detection of low bone mineral density by dual energy x ray absorptiometry in unsuspected suboptimally treated coeliac disease. Gut. 1995;37(2):220-224. No prevalence or incidence reported. [pmid: 7557572]. [pmcid: 1382722].
Walters J R. Bone mineral density in coeliac disease. Gut. 1994;35(2):150-151. No prevalence or incidence reported. [pmid: 8307462]. [pmcid: 1374486].
Warngard O, Stenhammar L, Ascher H, et al. Small bowel biopsy in Swedish paediatric clinics. Acta Paediatr. 1996;85(2):240-241. No prevalence or incidence reported. [pmid: 8640058].
Wasmuth H E, Matern S. Nutrition in childhood and immune-mediated diseases. Ann Nestle. 2002;60(1):22-31. No prevalence or incidence reported.
Weile B, Cavell B, Nivenius K, et al. Striking differences in the incidence of childhood celiac disease between Denmark and Sweden: a plausible explanation. J Pediatr Gastroenterol Nutr. 1995;21(1):64-68. Serology screen <1990. [pmid: 8576817].
Weile B, Krasilnikoff P A. Low incidence rates by birth of symptomatic coeliac disease in a Danish population of children. Acta Paediatr. 1992;81(5):394-398. Serology screen <1990. [pmid: 1498504].
Weile B. Aspects of classic symptomatic childhood coeliac disease in Denmark: Retrospectively illustrated by local, regional, and national studies. APMIS Suppl. 2003;111(113):5-46. Review article. [pmid: 14626049].
Weile Birgitte, Heegaard Niels H H, Hoier-Madsen Mimi, et al. Tissue transglutaminase and endomysial autoantibodies measured in an historical cohort of children and young adults in whom coeliac disease was suspected. Eur J Gastroenterol Hepatol. 2002;14(1):71-76. No prevalence or incidence reported. [pmid: 11782578].
Weinstein W M, Brow J R, Parker F, et al. The small intestinal mucosa in dermatitis herpetiformis. II. Relationship of the small intestinal lesion to gluten. Gastroenterology. 1971;60(3):362-369. No prevalence or incidence reported. [pmid: 5554078].
Weir D G, Hourihane D O. Coeliac disease during the teenage period: the value of serial serum folate estimations. Gut. 1974;15(6):450-457. No prevalence or incidence reported. [pmid: 4851068]. [pmcid: 1413001].
Weir D G. The pathogenesis of folic acid deficiency in man. Ir J Med Sci. 1974;143(1):3-20. No prevalence or incidence reported. [pmid: 4814742].
Weizman Z, Ben Zion Y Z, Binsztok M, et al. Correlation of clinical characteristics and small bowel histopathology in celiac disease. J Pediatr Gastroenterol Nutr. 1997;24(5):555-558. No prevalence or incidence reported. [pmid: 9161951].
Weizman Z, Stringer D A, Durie P R. Radiologic manifestations of malabsorption: a nonspecific finding. Pediatrics. 1984;74(4):530-533. No prevalence or incidence reported. [pmid: 6483519].
Weizman Z, Vardi O, Binsztok M. Dermatoglyphic (fingerprint) patterns in celiac disease. J Pediatr Gastroenterol Nutr. 1990;10(4):451-453. No prevalence or incidence reported. [pmid: 2358976].
West Joe, Logan Richard F A, Card Tim R, et al. Fracture risk in people with celiac disease: a population-based cohort study. Gastroenterology. 2003;125(2):429-436. No prevalence or incidence reported. [pmid: 12891545].
West R J, Fosbrooke A S, Lloyd J K. Treatment of children with familial hypercholesterolaemia. Postgrad Med J. 1975;51(8):Suppl 82-Suppl 87. No prevalence or incidence reported. [pmid: 1052928].
Westerholm-Ormio Mia, Vaarala Outi, Pihkala Paivi, et al. Immunologic activity in the small intestinal mucosa of pediatric patients with type 1 diabetes. Diabetes. 2003;52(9):2287-2295. No prevalence or incidence reported. [pmid: 12941768].
Westman E, Ambler G R, Royle M, et al. Children with coeliac disease and insulin dependent diabetes mellitus--growth, diabetes control and dietary intake. Journal of Pediatric Endocrinology & Metabolism - Jpem. 1999;12(3):433-442. No prevalence or incidence reported. [pmid: 10821223].
Wharton B A. Coeliac disease in childhood. Br J Hosp Med. 1974;12(4):452-466. No prevalence or incidence reported.
Wharton B, Wharton P. Nutrition in adolescence. Nutr Health. 1987;4(4):195-203. No prevalence or incidence reported. [pmid: 3554043].
White A G, Barnetson R S C, Da Costa J A G, et al. The incidence of HL A antigens in dermatitis herpetiformis. Br J Dermatol. 1973;89(2):133-136. No prevalence or incidence reported. [pmid: 4726888].
White T T, Slavotinek A H. Results of surgical treatment of chronic pancreatitis. Report of 142 cases. Ann Surg. 1979;189(2):217-224. No prevalence or incidence reported. [pmid: 426554]. [pmcid: 1397031].
Whitfield C R. Obstetric sprue. J Obstet Gynaecol Br Commonw. 1970;77(7):577-586. No prevalence or incidence reported. [pmid: 5458768].
Whorwell P J, Alderson M R, Foster K J, et al. Death from ischaemic heart-disease and malignancy in adult patients with coeliac disease. Lancet. 1976;2(7977):113-114. No prevalence or incidence reported. [pmid: 59182].
Wicks A C, Clain D J. Chronic pancreatitis in African diabetics. Am J Dig Dis. 1975;20(1):1-8. No prevalence or incidence reported. [pmid: 1115050].
Wicks A C, Jones J J. Ethnic differences in coronary heart disease. South African Medical Journal. Suid-Afrikaanse Tydskrif Vir Geneeskunde. 1973;47(9):362. No prevalence or incidence reported. [pmid: 4690390].
Wiggins H S, Pearson J R, Walker J G, et al. Incidence and significance of faecal hydroxystearic acid in alimentary disease. Gut. 1974;15(8):614-621. No prevalence or incidence reported. [pmid: 4418840]. [pmcid: 1413027].
Williams A J, Annis P, Lock R J, et al. Evaluation of a high-throughput second antibody radiobinding assay for measuring IgA antibodies to human tissue transglutaminase. J Immunol Methods. 1999;228(12):81-85. No prevalence or incidence reported. [pmid: 10556545].
Williams A J, Asquith P, Stableforth D E. Susceptibility to tuberculosis in patients with coeliac disease. Tubercle. 1988;69(4):267-274. No prevalence or incidence reported. [pmid: 3257005].
Williams A J, Norcross A J, Lock R J, et al. The high prevalence of autoantibodies to tissue transglutaminase in first-degree relatives of patients with type 1 diabetes is not associated with islet autoimmunity. Diabetes Care. 2001;24(3):504-509. Not a relevant screening group. [pmid: 11289476].
Williams C N, Dickson R C. Cholestyramine and medium-chain triglyceride in prolonged management of patients subjected to ileal resection or bypass. Can Med Assoc J. 1972;107(7):626-631. No prevalence or incidence reported. [pmid: 4665095]. [pmcid: 1940965].
Williamson Debbie, Marsh Michael N. Celiac disease. Mol Biotechnol. 2002;22(3):293-299. No prevalence or incidence reported. [pmid: 12448883].
Williamson N, Asquith P, Stokes L, et al. Anticonnective tissue and other antitissue ‘antibodies’ in the sera of patients with coeliac disease compared with the findings in a mixed hospital population. J Clin Pathol. 1976;29(6):484-494. No prevalence or incidence reported. [pmid: 939804]. [pmcid: 476105].
Willoughby J M T, Laitner S M. Audit of the investigation of iron deficiency anaemia in a distinct general hospital, with sample guidelines for future practice. Postgrad Med J. 2000;76(894):218-222. No prevalence or incidence reported. [pmid: 10727565].
Wills A J, Unsworth D J. The neurology of gluten sensitivity: Separating the wheat from the chaff. Curr Opin Neurol. 2002;15(5):519-523. No prevalence or incidence reported. [pmid: 12351994].
Wills A J. The neurology and neuropathology of coeliac disease. Neuropathol Appl Neurobiol. 2000;26(6):493-496. No prevalence or incidence reported. [pmid: 11123714].
Wilson M-M. Undernutrition in medical outpatients. Clin Geriatr Med. 2002;18(4):759-771. No prevalence or incidence reported. [pmid: 12608502].
Winklhofer-Roob B M, Rossipal E, Lanzer G. Human leucocyte class I and II antigens in coeliac disease: a study in an Austrian paediatric population. Eur J Pediatr. 1991;150(10):704-707. No prevalence or incidence reported. [pmid: 1915480].
Witas H W, Mlynarski W, Rozalski M, et al. Study of Polish coeliac patients: HLA-DQ amino acid variants involved in antigen presentation. Cent-Eur J Immunol. 1997;22(4):266-271. No prevalence or incidence reported.
Witas H W, Mlynarski W, Sychowski R. Polymorphism of genes located on chromosome 2q is associated with coeliac disease. Cent-Eur J Immunol. 2001;26(1):31-36. No prevalence or incidence reported.
Wolters Victorein, Vooijs-Moulaert Anne, Burger Huib, et al. Human tissue transglutaminase enzyme linked immunosorbent assay outperforms both the guinea pig based tissue transglutaminase assay and anti-endomysium antibodies when screening for coeliac disease. Eur J Pediatr. 2002;161(5):284-287. No prevalence or incidence reported. [pmid: 12012226].
Wonke B. Clinical management of beta-thalassemia major. Semin Hematol. 2001;38(4):350-359. No prevalence or incidence reported. [pmid: 11605170].
Woodruff C W. Milk intolerances. Nutr Rev. 1976;34(2):33-37. No prevalence or incidence reported. [pmid: 768821].
Woods R K, Stoney R M, Raven J, et al. Reported adverse food reactions overestimate true food allergy in the community. Eur J Clin Nutr. 2002;56(1):31-36. No prevalence or incidence reported. [pmid: 11840177].
Woods Rosalie K, Thien Frank, Raven Joan, et al. Prevalence of food allergies in young adults and their relationship to asthma, nasal allergies, and eczema. Annals of Allergy, Asthma & Immunology - Official Publication of the American College of Allergy, Asthma, & Immunology. 2002;88(2):183-189. No prevalence or incidence reported. [pmid: 11868923].
Woolley N, Holopainen P, Bourgain C, et al. CD80 (B7-1) and CD86 (B7-2) genes and genetic susceptibility to coeliac disease. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 2002;29(4):331-333. No prevalence or incidence reported. [pmid: 12121279].
Woolley Niina, Holopainen Paivi, Ollikainen vesa, et al. A new locus for coeliac disease mapped to chromosome 15 in a population isolate. Hum Genet. 2002;111(1):40-45. No prevalence or incidence reported. [pmid: 12136234].
Wordsworth B P, Salmon M. The HLA class II component of susceptibility to rheumatoid arthritis. Bailliere's Clin Rheumatol. 1992;6(2):325-336. No prevalence or incidence reported. [pmid: 1525842].
Wordsworth P. PCR-SSO typing in HLA-disease association studies. European Journal of Immunogenetics - Official Journal of the British Society for Histocompatibility and Immunogenetics. 1991;18(12):139-146. No prevalence or incidence reported. [pmid: 2069941].
Wright D H. Enteropathy associated T cell lymphoma. Cancer Surv. 1997;30(-):249-261. No prevalence or incidence reported. [pmid: 9547996].
Wright D H. The major complications of coeliac disease. Bailliere's Clin Gastroenterol. 1995;9(2):351-369. No prevalence or incidence reported. [pmid: 7549031].
Wu T T, Hamilton S R. Lymphocytic gastritis: association with etiology and topology. Am J Surg Pathol. 1999;23(2):153-158. No prevalence or incidence reported. [pmid: 9989841].
Wucherpfennig K W. Insights into autoimmunity gained from structural analysis of MHC-peptide complexes. Curr Opin Immunol. 2001;13(6):650-656. No prevalence or incidence reported. [pmid: 11677085].
Wurm P, Wicks A C. Iron deficiency anaemia - A clinical challenge. Postgrad Med J. 2000;76(894):193-194. No prevalence or incidence reported. [pmid: 11009583].
Wyburn G M. The scanning micrograph as a clinical dimension. N Z Med J. 1974;80(520):51-56. No prevalence or incidence reported. [pmid: 4529497].
Yamashiro Y. Pediatric gastroenterology in Japan: A personal perspective. J Pediatr Gastroenterol Nutr. 2002;34(5):493-495. No prevalence or incidence reported. [pmid: 12192174].
Yeboah F A, White D. AlphaB-crystallin expression in celiac disease - a preliminary study. Croat Med J. 2001;42(5):523-526. No prevalence or incidence reported. [pmid: 11593501].
Yiannakou J Y, Brett P M, Morris M A, et al. Family linkage study of the T-cell receptor genes in coeliac disease. Ital J Gastroenterol Hepatol. 1999;31(3):198-201. No prevalence or incidence reported. [pmid: 10379479].
Yong J M. Cause of raised serum-alkaline-phosphatase after partial gastrectomy and in other malabsorption states. Lancet. 1966;1(7447):1132-1134. No prevalence or incidence reported. [pmid: 4161121].
Young W F, Pringle E M. 110 children with coeliac disease, 1950-1969. Arch Dis Child. 1971;46(248):421-436. No prevalence or incidence reported. [pmid: 5109407].
Zachor D A, Mroczek-Musulman E, Brown P. Prevalence of celiac disease in Down syndrome in the United States. J Pediatr Gastroenterol Nutr. 2000;31(3):275-279. Not a relevant screening group. [pmid: 10997372].
Zadik Z, Kowarski A. Incidence of neurosecretory dysfunction among children aged 6–14 years in Rehovot, Israel. Acta Paediatrica Scandinavica.Supplement 1989;34977–83. No prevalence or incidence reported
Zalev A H, Gardiner G W, Warren R E. NSAID injury to the small intestine. Abdom Imaging. 1998;23(1):40-44. No prevalence or incidence repoted. [pmid: 9437061].
Zauli D, Grassi A, Granito A, et al. Prevalence of silent coeliac disease in atopics. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2000;32(9):775-779. No prevalence or incidence reported. [pmid: 11215557].
Zelissen P M, Bast E J, Croughs R J. Associated autoimmunity in Addison's disease. J Autoimmun. 1995;8(1):121-130. No prevalence or incidence reported. [pmid: 7734032].
Zhong F, McCombs C C, Olson J M, et al. An autosomal screen for genes that predispose to celiac disease in the western counties of Ireland. Nat Genet. 1996;14(3):329-333. No prevalence or incidence reported. [pmid: 8896565].
Ziegler Anette, Schmid Sandra, Huber Doris, et al. Early infant feeding and risk of developing type 1 diabetes-associated autoantibodies. Jama - the Journal of the American Medical Association. 2003;290(13):1721-1728. No prevalence or incidence reported. [pmid: 14519706].
Ziem G E. Profile of patients with chemical injury and sensitivity, part II. Int J Toxicol. 1999;18(6):401-409. No prevalence or incidence reported.
Zins B J, Tremaine W J, Carpenter H A. Collagenous colitis: mucosal biopsies and association with fecal leukocytes. Mayo Clin Proc. 1995;70(5):430-433. No prevalence or incidence reported. [pmid: 7731251].
Zipser Robert D, Patel Sunil, Yahya Kareem Z, et al. Presentations of adult celiac disease in a nationwide patient support group. Dig Dis Sci. 2003;48(4):761-764. No prevalence or incidence reported. [pmid: 12741468].
Zollinger R M. Islet cell tumors of the pancreas and the alimentary tract. Am J Surg. 1975;129(2):102-110. No prevalence or incidence reported. [pmid: 164136].
Zubillaga P, Vitoria J C, Arrieta A, et al. Down Syndrome and celiac disease. J Pediatr Gastroenterol Nutr. 1993;16(2):168-171. No prevalence or incidence reported. [pmid: 8450384].
Zucca E, Roggero E, Bertoni F, et al. Primary extranodal non-Hodgkin's lymphomas. Part 1: Gastrointestinal, cutaneous and genitourinary lymphomas. Ann Oncol. 1997;8(8):727-737. No prevalence or incidence reported. [pmid: 9332679].

### Objective 3 - Celiac Associated Lymphoma

Abdulkarim A S, Burgart L J, See J, et al. Etiology of nonresponsive celiac disease: results of a systematic approach. Am J Gastroenterol. 2002;97(8):2016-2021. Does not address the question. [pmid: 12190170].
Acalovschi M. Coeliac disease and lymphoma. Rom J Gastroenterol. 2001;10(4):317-320. Review article.
Al Mondhiry H. Primary lymphomas of the small intestine: east-west contrast. Am J Hematol. 1986;22(1):89-105. Review article. [pmid: 3953568].
Aljurf M D, Owaidah T W, Ezzat A, et al. Antigen- and/or immune-driven lymphoproliferative disorders. Ann Oncol. 2003;14(11):1595-1606. Not about celiac and GI lymphoma. [pmid: 14581266].
Andersson H, Dotevall G, Mobacken H. Malignant mesenteric lymphoma in a patient with dermatitis herpetiformis, hypochlorhydria, and small-bowel abnormalities. Scand J Gastroenterol. 1971;6(5):397-399. Does not address the question. [pmid: 5093527].
Anonymous. Coeliac disease in the elderly. Lancet 1984;1(8380):775–776. Not about celiac and GI lymphoma
Anonymous. A new type intestinal lymphoma. J Clin Pathol Mol Pathol 2002;55(5):314Not about celiac and GI lymphoma
Anonymous. Primary gut lymphomas. Lancet 1991;337(8754):1384–1385. Not about celiac and GI lymphoma
Anonymous. A guide for patients. Pract Gastroenterol 2002;26(11):58–61. Not about celiac and GI lymphoma
Aozasa K. Villous atrophy with crypt hyperplasia in malignant histiocytosis of the nose. J Clin Pathol. 1982;35(6):606-610. Not about celiac and GI lymphoma. [pmid: 7085911]. [pmcid: 497733].
Ashton-Key M, Diss T C, Pan L, et al. Molecular analysis of T-cell clonality in ulcerative jejunitis and enteropathy-associated T-cell lymphoma. Am J Pathol. 1997;151(2):493-498. Does not address the question. [pmid: 9250161]. [pmcid: 1857986].
Asquith P. Adult coeliac disease and malignancy. Ir Med J. 1974;67(15):417-420. Review article. [pmid: 4411887].
Austad W I, Cornes J S, Gough K R, et al. Steatorrhea and malignant lymphoma. The relationship of malignant tumors of lymphoid tissue and celiac disease. Am J Dig Dis. 1967;12(5):475-490. Does not address the question. [pmid: 6026426].
Baer A N, Bayless T M, Yardley J H. Intestinal ulceration and malabsorption syndromes. Gastroenterology. 1980;79(4):754-765. Not about celiac and GI lymphoma. [pmid: 7409396].
Bagdi E, Diss T C, Munson P, et al. Mucosal intra-epithelial lymphocytes in enteropathy-associated T-cell lymphoma, ulcerative jejunitis, and refractory celiac disease constitute a neoplastic population. Blood. 1999;94(1):260-264. Does not address the question. [pmid: 10381521].
Bank S, Marks I N, Novis B. Progress in small-bowel physiology and disease. South African Medical Journal. Suid-Afrikaanse Tydskrif Vir Geneeskunde. 1971;45(41):1141-1144. Not about celiac and GI lymphoma. [pmid: 5129890].
Barry R E. Coeliac disease and malignancy. Tijdschr Gastroenterol. 1973;16(1):23-34. Does not address the question. [pmid: 4707921].
Barry R E, Read A E. Coeliac disease and malignancy. Qjm - Monthly Journal of the Association of Physicians. 1973;42(168):665-675. Not about celiac and GI lymphoma.
Barry R E, Read A E. Two types of ‘coeliac’ disease?. Gut. 1972;13(10):846-847. Not about celiac and GI lymphoma. [pmid: 5087098].
Barry R E, Baker P, Read A E. Coeliac disease. The clinical presentation. Clin Gastroenterol. 1974;3(1):55-69. Not about celiac and GI lymphoma. [pmid: 4525532].
Barry R E, Morris J S, Kenwright S, et al. Coeliac disease and malignancy. The possible importance of familial involvement. Scand J Gastroenterol. 1971;6(3):205-207. Not about celiac and GI lymphoma. [pmid: 4254382].
Bell S, Green P H R, Kagnoff M F. American gastroenterological association medical position statement: Celiac sprue. Gastroenterology. 2001;120(6):1522-1525. Not about celiac and GI lymphoma. [pmid: 11313323].
Berndt H. Malabsorption in cancer of and outside the bowel. Digestion. 1968;1(5):305-310. Not about celiac and GI lymphoma. [pmid: 5727779].
Biagi F, Corazza G R. Defining gluten refractory enteropathy. Eur J Gastroenterol Hepatol. 2001;13(5):561-565. Not about celiac and GI lymphoma. [pmid: 11396537].
Biagi F, Lorenzini P, Corazza G R. Literature review on the clinical relationship between ulcerative jejunoileitis, coeliac disease, and enteropathy-associated T-cell. Scand J Gastroenterol. 2000;35(8):785-790. Review article. [pmid: 10994614].
Bontems P, Deprettere A, Cadranel S, et al. The coeliac iceberg: A consensus in paediatrics. Acta Gastro-Enterol Belg. 2000;63(2):157-162. Not about celiac and GI lymphoma.
Booth S N, King J P G, Leonard J C, et al. Serum carcinoembryonic antigen in clinical disorders. Gut. 1973;14(10):794-799. Not about celiac and GI lymphoma. [pmid: 4758660]. [pmcid: 1412786].
Boucher B J, Wright J T. Steatorrhoea and jejunal reticulum cell sarcoma occurring in a patient on long-term colchicine therapy for gout. Postgrad Med J. 1973;49(568):106-107. Not about celiac and GI lymphoma. [pmid: 4580807].
Bourke M A, McLoughlin D M, Stevens F M, et al. Serum lysozyme: is it a useful marker of malignant lymphoma in coeliac disease?. Ir J Med Sci. 1983;152(3):125-128. Not about celiac and GI lymphoma. [pmid: 6853114].
Brandborg L L. Histologic diagnosis of diseases of malabsorption. Am J Med. 1979;67(6):999-1006. Not about celiac and GI lymphoma. [pmid: 517556].
Brandt L, Hagander B, Norden A, et al. lymphoma of the small intestine in adult coeliac disease. Acta Med Scand. 1978;204(6):467-470. Does not address the question. [pmid: 367082].
Brunt P W, Sircus W, Maclean N. Neoplasia and the coeliac syndrome in adults. Lancet. 1969;1(7587):180-184. Not about celiac and GI lymphoma. [pmid: 4178419].
Brunton F J, Guyer P B. Malignant histiocytosis and ulcerative jejunitis of the small intestine. Clin Radiol. 1983;34(3):291-295. Not about celiac and GI lymphoma. [pmid: 6839654].
Brzechwa-Ajdukiewicz A, McCarthy C F, Austad W, et al. Carcinoma, villous atrophy, and steatorrhoea. Gut. 1966;7(6):572-577. Not about celiac and GI lymphoma. [pmid: 5957507]. [pmcid: 1552634].
Buckley D B, English J, Molloy W, et al. Dermatitis herpetiformis: a review of 119 cases. Clin Exp Dermatol. 1983;8(5):477-487. Not about celiac and GI lymphoma. [pmid: 6641006].
Burrows F G, Toye D K. Coeliac disease. Barium studies. Clin Gastroenterol. 1974;3(1):91-107. Not about celiac and GI lymphoma. [pmid: 4209631].
Cammarota G, Tursi A, Papa A, et al. Helicobacter pylori, gastric mucosa-associated lymphoid tissue and autoimmune thyroid diseases. Gastroenterol Int. 1997;10(SUPPL. 1):43-45. Not about celiac and GI lymphoma.
Carbonnel F, D'Almagne H, Lavergne A, et al. The clinicopathological features of extensive small intestinal CD4 T cell infiltration. Gut. 1999;45(5):662-667. Not about celiac and GI lymphoma. [pmid: 10517900]. [pmcid: 1727728].
Carbonnel F, Grollet-Bioul L, Brouet J C, et al. Are complicated forms of celiac disease cryptic T-cell lymphomas?. Blood. 1998;92(10):3879-3886. Does not address the question. [pmid: 9808581].
Carroccio A, Iannitto E, Di Prima L, et al. Screening for celiac disease in non-Hodgkin's lymphoma patients: a serum anti-transglutaminase-based approach. Dig Dis Sci. 2003;48(8):1530-1536. Not about celiac and GI lymphoma. [pmid: 12924648].
Casellas F, Chicharro L, Malagelada J R. Potential usefulness of hydrogen breath test with D-xylose in clinical management of intestinal malabsorption. Dig Dis Sci. 1993;38(2):321-327. Not about celiac and GI lymphoma. [pmid: 8425444].
Catassi C, Fabiani E, Corrao G, et al. Risk of non-Hodgkin lymphoma in celiac disease. Jama - the Journal of the American Medical Association. 2002;287(11):1413-1419. Risk of CD in lymphoma. [pmid: 11903028].
Ceccarelli M, Cortigiani L, Ughi C, et al. Placental isoferritin as a marker of immune system involvement in coeliac disease. Riv Ital Pediatr. 1990;16(3):300-302. Not about celiac and GI lymphoma.
Cellier C, Cuillerier E, Patey-Mariaud de, et al. Push enteroscopy in celiac sprue and refractory sprue. Gastrointest Endosc. 1999;50(5):613-617. Not about celiac and GI lymphoma. [pmid: 10536314].
Cellier C, Delabesse E, Helmer C, et al. Refractory sprue, coeliac disease, and enteropathy-associated T-cell lymphoma. French Coeliac Disease Study group. Lancet. 2000;356(9225):203-208. Pathogenesis only. [pmid: 10963198].
Cellier C, Patey N, Mauvieux L, et al. Abnormal intestinal intraepithelial lymphocytes in refractory sprue. Gastroenterology. 1998;114(3):471-481. Not about celiac and GI lymphoma. [pmid: 9496937].
Cello J P. Inflammatory and malignant diseases of the small bowel causing malabsorption. Clin Gastroenterol. 1983;12(2):511-532. Not about celiac and GI lymphoma. [pmid: 6872312].
Cerf-Bensussan N, Brousse N, Cellier C. From hyperplasia to T cell lymphoma. Gut. 2002;51(3):304-305. Review article. [pmid: 12171943]. [pmcid: 1773362].
Chantar C, Escartin P, Plaza A G. Diffuse plasma cell infiltration of the small intestine with malabsorption associated to IgA monoclonal gammapathy. Cancer. 1974;34(5):1620-1630. Not about celiac and GI lymphoma. [pmid: 4214600].
Cheng H, Wang J, Zhang C, et al. Clinicopathologic study of mucosa-associated lymphoid tissue lymphoma in gastroscopic biopsy. World Journal of Gastroenterology - Wjg. 2003;9(6):1270-1272. Not about celiac and GI lymphoma. [pmid: 14669346].
Chott A, Dragosics B, Radaszkiewicz T. Peripheral T-cell lymphomas of the intestine. Am J Pathol. 1992;141(6):1361-1371. Does not address the question. [pmid: 1466400]. [pmcid: 1886751].
Chott A, Haedicke W, Mosberger I, et al. Most CD56sup + intestinal lymphomas are CD8sup +CD5sup - T-cell lymphomas of monomorphic small to medium size histology. Am J Pathol. 1998;153(5):1483-1490. Not about celiac and GI lymphoma. [pmid: 9811340]. [pmcid: 1853407].
Ciacci C, Squillante A, Rendina D, et al. Helicobacter pylori infection and peptic disease in coeliac disease. Eur J Gastroenterol Hepatol. 2000;12(12):1283-1287. Not about celiac and GI lymphoma. [pmid: 11192316].
Ciclitira Paul J, Moodie Simon J. Transition of care between paediatric and adult gastroenterology. Coeliac disease. Best Practice & Research. Clinical Gastroenterology. 2003;17(2):181-195. Not about celiac and GI lymphoma. [pmid: 12676114].
Cluysenaer O J J, Van Tongeren J H M. The natural history of coeliac sprue, and factors which may influence it. Neth J Med. 1978;21(1):35-43. Not about celiac and GI lymphoma. [pmid: 634415].
Collin P, Reunala T, Pukkala E, et al. Coeliac disease--associated disorders and survival. Gut. 1994;35(9):1215-1218. Double publication of included data. [pmid: 7959226]. [pmcid: 1375696].
Connon J J, McFarland J, Kelly A. Acute abdominal complications of coeliac disease. Scand J Gastroenterol. 1975;10(8):843-846. Not about celiac and GI lymphoma. [pmid: 1105763].
Cooke W T, Thompson H, Williams J A. Malignancy and adult coeliac disease. Gut. 1969;10(2):108-111. Not a controlled study. [pmid: 5370097]. [pmcid: 1552789].
Cooper B T, Read A E. Small intestinal lymphoma. World J Surg. 1985;9(6):930-937. Review article. [pmid: 3936285].
Cooper B T, Read A E. Coeliac disease and lymphoma. Qjm - Monthly Journal of the Association of Physicians. 1987;63(240):269-274. Review article.
Cooper B T, Holmes G K T, Ferguson R. Celiac disease and malignancy. Medicine. 1980;59(4):249-261. Not a controlled study. [pmid: 7392945].
Cooper B T, Holmes G K, Cooke W T. lymphoma risk in coeliac disease of later life. Digestion. 1982;23(2):89-92. Double publication of included data. [pmid: 7095316].
Cooper B T, Ukabam S O, Barry R E, et al. Serum lysozyme activity in coeliac disease: A possible aid to the diagnosis of malignant change. J Clin Pathol. 1981;34(12):1358-1360. Not about celiac and GI lymphoma. [pmid: 7328182]. [pmcid: 494601].
Cooper D L, Doria R, Salloum E. Primary gastrointestinal lymphomas. Gastroenterologist. 1996;4(1):54-64. Not about celiac and GI lymphoma. [pmid: 8689146].
Corazza G R, Di Stefano M, Ciccocioppo R, et al. Immune-mediated complications of coeliac disease. Int J Immunopathol Pharmacol. 1997;10(2 Suppl):83-85. Not about celiac and GI lymphoma.
Corazza G R, Zoli G, Di Sabatino A, et al. A reassessment of splenic hypofunction in celiac disease. Am J Gastroenterol. 1999;94(2):391-397. Not about celiac and GI lymphoma. [pmid: 10022635].
Cornes J S. Hodgkin's disease of the gastrointestinal tract. Proc R Soc Med. 1967;60(8):732-733. Not about celiac and GI lymphoma. [pmid: 6035388]. [pmcid: 1901915].
Crabbe P A, Heremans J F. Normal and defective production of immunoglobulins in the intestinal tract. Bibl Paediatr 1968;87161–181. Not about celiac and GI lymphoma
Cronin C C, Shanahan F. Exploring the iceberg - The spectrum of celiac disease. Am J Gastroenterol. 2003;98(3):518-520. Not about celiac and GI lymphoma. [pmid: 12650779].
Crump M, Gospodarowicz M, Shepherd F A. Lymphoma of the gastrointestinal tract. Semin Oncol. 1999;26(3):324-337. Review article. [pmid: 10375089].
Cuillerier E, Landi B, Cellier C. Is push enteroscopy useful in patients with malabsorption of unclear origin?. Am J Gastroenterol. 2001;96(7):2103-2106. Not about celiac and GI lymphoma. [pmid: 11467639].
Cuoco L, Cammarota G, Tursi A, et al. Disappearance of gastric mucosa-associated lymphoid tissue in coeliac patients after gluten withdrawal. Scand J Gastroenterol. 1998;33(4):401-405. Not about celiac and GI lymphoma. [pmid: 9605262].
Czaja A J. Autoimmune liver disease. Curr Opin Gastroenterol. 1999;15(3):240-248. Not about celiac and GI lymphoma. [pmid: 17023951].
D'Agostino L, Ciacci C, Daniele B, et al. Postheparin plasma diamine oxidase in subjects with small bowel mucosal atrophy. Dig Dis Sci. 1987;32(3):313-317. Not about celiac and GI lymphoma. [pmid: 3102190].
D'Agostino L, Contegiacomo A, Pignata S, et al. Plasma postheparin diamine oxidase in patients with small intestinal lymphoma. Cancer. 1991;67(2):511-515. Not about celiac and GI lymphoma. [pmid: 1898707].
D'Agostino L, Daniele B, Pignata S, et al. Postheparin plasma diamine oxidase in subjects with small bowel disease. Diagnostic efficiency of a simplified test. Digestion. 1988;41(1):46-54. Not about celiac and GI lymphoma. [pmid: 3144470].
Daum S, Weiss D, Hummel M, et al. Frequency of clonal intraepithelial T lymphocyte proliferations in enteropathy-type intestinal T cell lymphoma, coeliac disease, and refractory sprue. Gut. 2001;49(6):804-812. Does not address the question. [pmid: 11709515]. [pmcid: 1728529].
David T J, Ajdukiewicz A B, Read A E. Dermal and epidermal ridge atrophy in celiac sprue. Gastroenterology. 1973;64(4):539-544. Not about celiac and GI lymphoma. [pmid: 4700769].
de Bruin P C, Jiwa N M, Oudejans J J, et al. Epstein-Barr virus in primary gastrointestinal T cell lymphomas. Association with gluten-sensitive enteropathy, pathological features, and immunophenotype. Am J Pathol. 1995;146(4):861-867. Not about celiac and GI lymphoma. [pmid: 7717453]. [pmcid: 1869254].
de Bruin P C, Kummer J A, van der V, et al. Granzyme B-expressing peripheral T-cell lymphomas: neoplastic equivalents of activated cytotoxic T cells with preference for mucosa-associated lymphoid tissue localization. Blood. 1994;84(11):3785-3791. Not about celiac and GI lymphoma. [pmid: 7524749].
De Giacomo C, Gianatti A, Negrini R, et al. Lymphocytic gastritis: a positive relationship with celiac disease. Eur J Pediatr. 1994;124(1):57-62. Not about celiac and GI lymphoma.
Deprez Pierre H, Sempoux Christine, De Saeger, et al. Expression of cholecystokinin in the duodenum of patients with coeliac disease: respective role of atrophy and lymphocytic infiltration. Clinical Science (London, England - 1979). 2002;103(2):171-177. Not about celiac and GI lymphoma. [pmid: 12149109].
Devi Rampertab S, Fleischauer A, Neugut A I, et al. Risk of duodenal adenoma in celiac disease. Scand J Gastroenterol. 2003;38(8):831-833. Not about celiac and GI lymphoma. [pmid: 12940435].
Dewar D, Pereira S P, Ciclitira P J. The pathogenesis of coeliac disease. Int J Biochem Cell Biol. 2004;36(1):17-24. Not about celiac and GI lymphoma. [pmid: 14592529].
Dickey W. Colon neoplasia co-existing with coeliac disease in older patients: coincidental, probably; important, certainly. Scand J Gastroenterol. 2002;37(9):1054-1056. Not about celiac and GI lymphoma. [pmid: 12374231].
Dieterich W, Ehnis T, Bauer M, et al. Identification of tissue transglutaminase as the autoantigen of celiac disease. Nat Med. 1997;3(7):797-801. Review article. [pmid: 9212111].
Dinari G, Zahavi I, Marcus H, et al. Placental ferritin in coeliac disease: relation to clinical stage, origin, and possible role in the pathogenesis of malignancy. Gut. 1991;32(9):999-1003. Does not address the question. [pmid: 1916505]. [pmcid: 1379037].
Doe W F. An overview of intestinal immunity and malabsorption. Am J Med. 1979;67(6):1077-1084. Not about celiac and GI lymphoma. [pmid: 117706].
Douglas A P. The immunological basis of coeliac disease. Front Gastrointest Res 1975;149–73. Not about celiac and GI lymphoma
Driessen A, Ectors N. Lymphomas of the gastro-intestinal tract: Uncommon types: LYMPHOMES DU TRACTUS GASTRO-INTESTINAL: TYPES RARES. Acta Endoscopica. 2003;33(3):327-345. Not about celiac and GI lymphoma.
Duffy L F. Gastrointestinal manifestations in AIDS. Pediatr AIDS HIV Infect. 1993;4(3):151-156. Not about celiac and GI lymphoma.
Dutz W, Asvadi S, Sadri S, et al. Intestinal lymphoma and sprue: a systematic approach. Gut. 1971;12(10):804-810. Does not address the question. [pmid: 4941685]. [pmcid: 1411879].
Egan C A, O'Loughlin S, Gormally S, et al. Dermatitis Herpetiformis: a review of fifty-four patients. Ir J Med Sci. 1997;166(4):241-244. Not about celiac and GI lymphoma. [pmid: 9394075].
Egan L J, Walsh S V, Stevens F M, et al. Celiac-associated lymphoma. A single institution experience of 30 cases in the combination chemotherapy era. J Clin Gastroenterol. 1995;21(2):123-129. Does not address the question. [pmid: 8583077].
Elsborg L, Mosbech J. Sprue: a follow-up study of an old series. Dan Med Bull. 1978;25(5):205-206. Not about celiac and GI lymphoma. [pmid: 699635].
Ermacora E, Prampolini L, Tribbia G. Long-term follow-up of dermatitis herpetiformis in children. J Am Acad Dermatol. 1986;15(1):24-30. Not about celiac and GI lymphoma. [pmid: 3722506].
Farrell R J, Kelly C P. Diagnosis of celiac sprue. Am J Gastroenterol. 2001;96(12):3237-3246. Not about celiac and GI lymphoma. [pmid: 11774931].
Farstad I N, Lundin K E A. Gastrointestinal intraepithelial lymphocytes and T cell lymphomas. Gut. 2003;52(2):163-164. Not about celiac and GI lymphoma. [pmid: 12524390]. [pmcid: 1774974].
Farstad I N, Johansen F-E, Vlatkovic L, et al. Heterogeneity of intraepithelial lymphocytes in refractory sprue: Potential implications of CD30 expression. Gut. 2002;51(3):372-378. Not about celiac and GI lymphoma. [pmid: 12171959]. [pmcid: 1773363].
Farthing M J, Rees L H, Edwards C R, et al. Male gonadal function in coeliac disease: 2. Sex hormones. Gut. 1983;24(2):127-135. Not about celiac and GI lymphoma. [pmid: 6682819]. [pmcid: 1420172].
Feeley K M, Heneghan M A, Stevens F M, et al. Lymphocytic gastritis and coeliac disease: evidence of a positive association. J Clin Pathol. 1998;51(3):207-210. Not about celiac and GI lymphoma. [pmid: 9659261]. [pmcid: 500640].
Fehmers M C, Wilderink F, Oushoorn H H, et al. Gluten-sensitive enteropathy and intestinal lymphoreticulosis. A case report. Neth J Med. 1975;18(2):83-88. Not about celiac and GI lymphomaa. [pmid: 1107873].
Ferguson A, Kingstone K. Coeliac disease and malignancies. Acta Paediatr 1996;41278–81. Does not address the question
Ferguson R, Asquith P, Cooke W T. The cellular infiltrate of the jejunum in coeliac patients with complicating lymphoma. Gut. 1974;15(4):338-339. Not about celiac and GI lymphoma. [pmid: 4434954].
Ferguson R, Asquith P, Cooke W T. The jejunal cellular infiltrate in coeliac disease complicated by lymphoma. Gut. 1974;15(6):458-461. Not about celiac and GI lymphoma. [pmid: 4434954]. [pmcid: 1412999].
Festen H P. Intrinsic factor secretion and cobalamin absorption. Physiology and pathophysiology in the gastrointestinal tract. Scandinavian Journal of Gastroenterology.Supplement 1991;1881–7. Not about celiac and GI lymphoma
Finan P J, Thompson M R. Surgical presentation of small bowel lymphoma in adult coeliac disease. Postgrad Med J. 1980;56(662):859-861. Does not address the question. [pmid: 7267499].
Fine K D, Stone M J. Alpha-heavy chain disease, Mediterranean lymphoma, and immunoproliferative small intestinal disease: a review of clinicopathological features, pathogenesis, and differential diagnosis. Am J Gastroenterol. 1999;94(5):1139-1152. Not about celiac and GI lymphoma. [pmid: 10235185].
Fine K D, Lee E L, Meyer R L. Colonic histopathology in untreated celiac sprue or refractory sprue: is it lymphocytic colitis or colonic lymphocytosis?. Hum Pathol. 1998;29(12):1433-1440. Not about celiac and GI lymphoma. [pmid: 9865829].
Fisher C M. Neoplasia and the coeliac syndrome. Lancet. 1969;1(7597):730. Not about celiac and GI lymphoma. [pmid: 4186167].
Foss H D, Stein H. Pathology of intestinal lymphomas. Recent Results in Cancer Research.Fortschritte Der Krebsforschung.Progres Dans Les Recherches Sur Le Cancer 2000;15633–41. Not about celiac and GI lymphoma
Foster P N, Heatley R V, Losowsky M S. Natural killer cells in coeliac disease. J Clin Lab Immunol. 1985;17(4):173-176. Not about celiac and GI lymphoma. [pmid: 4068031].
Freeman H J. Survey of gastroenterologists on the diagnosis and treatment of adult patients with celiac disease in British Columbia. Can J Gastroenterol. 1998;12(2):149-152. Does not address the question. [pmid: 10206732].
Freeman H J. Hepatobiliary tract and pancreatic disorders in celiac disease. Can J Gastroenterol. 1997;11(1):77-81. Not about celiac and GI lymphoma. [pmid: 9459049].
Freeman H J. Celiac-associated autoimmune thyroid disease: A study of 16 patients with overt hypothyroidism: Maladie thyroidienne auto-immune de nature coeliaque: etude portant sur 16 patients atteints d'hypothyroidie averee. Can J Gastroenterol. 1995;9(5):242-246. Not about celiac and GI lymphoma.
Freeman H J. Clinical spectrum of biopsy defined celiac disease in the elderly. Can J Gastroenterol. 1995;9(1):42-46. Not about celiac and GI lymphoma.
Freeman H J. Neoplastic disorders in 100 patients with adult celiac disease. Can J Gastroenterol. 1996;10(3):163-166. Not about celiac and GI lymphoma. [pmid: 9113886].
Freeman H J. Free perforation due to intestinal lymphoma in biopsy-defined or suspected celiac disease. J Clin Gastroenterol. 2003;37(4):299-302. Not about celiac and GI lymphoma. [pmid: 14506386].
Freeman H J, Weinstein W M, Shnitka T K. Primary abdominal lymphoma. Presenting manifestation of celiac sprue or complicating dermatitis herpetiformis. Am J Med. 1977;63(4):585-594. Not about celiac and GI lymphoma. [pmid: 333913].
Freeman Hugh, Lemoyne Michel, Pare Pierre. Coeliac disease. Best Practice & Research. Clinical Gastroenterology. 2002;16(1):37-49. Review article. [pmid: 11977927].
Fry L. Dermatitis herpetiformis. Bailliere's Clinical Gastroenterology. 1995;9(2):371-393. Not about celiac and GI lymphoma. [pmid: 7549032].
Fry L, McMinn R M. Morphology and functional cytology of the small intestinal mucosa in malabsorptive disorders and other diseases. J Clin Pathol. 1966;19(3):260-265. Not about celiac and GI lymphoma. [pmid: 5937611]. [pmcid: 473250].
Fu K, Stewart J R. Radiotherapeutic management of small intestinal lymphoma with malabsorption. Cancer. 1973;31(2):286-290. Not about celiac and GI lymphoma. [pmid: 4569293].
Fundia A F, Gonzalez Cid M B, Bai J, et al. Chromosome instability in lymphocytes from patients with celiac disease. Clin Genet. 1994;45(2):57-61. Does not address the question. [pmid: 8004798].
Fundia A, Gomez J C, Maurino E et al. Chromosome instability in untreated adult celiac disease patients. Acta Paediatr 1996;41282–84. Does not address the question
Gale J, Simmonds P D, Mead G M, et al. Enteropathy-type intestinal T-cell lymphoma: clinical features and treatment of 31 patients in a single center. Journal of Clinical Oncology - Official Journal of the American Society of Clinical Oncology. 2000;18(4):795-803. Does not address the question. [pmid: 10673521].
Garioch J J. Dermatitis herpetiformis and its management. Prescr J. 1996;36(3):141-145. Not about celiac and GI lymphoma.
Gasbarrini G, Ciccocioppo R, De Vitis I, et al. Coeliac disease in the elderly. A multicentre Italian study. Gerontology. 2001;47(6):306-310. Not a controlled study. [pmid: 11721143].
Gasbarrini G, Miglio F, Serra M A, et al. Immunological studies of the jejunal mucosa in normal subjects and adult celiac patients. Digestion. 1974;10(2):122-128. Not about celiac and GI lymphoma. [pmid: 4601713].
Gawkrodger D J, Blackwell J N, Gilmour H M, et al. Dermatitis herpetiformis: diagnosis, diet and demography. Gut. 1984;25(2):151-157. Not about celiac and GI lymphoma. [pmid: 6693042]. [pmcid: 1432259].
Gay G J, Delmotte J S. Enteroscopy in small intestinal inflammatory diseases. Gastrointest Endosc Clin N Am. 1999;9(1):115-123. Not about celiac and GI lymphoma. [pmid: 9834320].
Gerson D E, Lewicki A M. Intramural small bowel hemorrhage: complication of sprue. Radiology. 1973;108(3):521-522. Not about celiac and GI lymphoma. [pmid: 4541875].
Gheorghe L, Gheorghe C, Aposteanu G, et al. Clinical spectrum of adult celiac disease in a referral center for Southern Romania. Associated disorders and short-term survival. Rom J Gastroenterol. 1996;5(4):223-228. Not about celiac and GI lymphoma.
Gill S S, Heuman D M, Mihas A A. Small intestinal neoplasms. J Clin Gastroenterol. 2001;33(4):267-282. Not about celiac and GI lymphoma. [pmid: 11588539].
Gillet H, Ferguson A, Frier B. Coeliac disease often co-exists with Type 1 diabetes mellitus. Pract Diabetes Int. 1998;15(4):117-120. Not about celiac and GI lymphoma.
Goerres M S, Meijer J W R, Wahab P J, et al. Azathioprine and prednisone combination therapy in refractory coeliac disease. Aliment Pharmacol Ther. 2003;18(5):487-494. Not a controlled study. [pmid: 12950421].
Goldberg H I, Sheft D J. Abnormalities in small intestine contour and caliber: a working classification. Radiol Clin North Am. 1976;14(3):461-475. Not about celiac and GI lymphoma. [pmid: 826981].
Goodwin P, Fry L. Reticulum cell sarcoma complicating dermatitis herpetiformis. Proc R Soc Med. 1973;66(7):625-626. Not about celiac and GI lymphoma. [pmid: 4582308]. [pmcid: 1645089].
Gould D J, Howell R. Dermatitis herpetiformis and reticulum cell sarcoma, a rare complication. Br J Dermatol. 1977;96(5):561-562. Not about celiac and GI lymphoma. [pmid: 326291].
Gourtsoyiannis N C, Nolan D J. lymphoma of the small intestine: radiological appearances. Clin Radiol. 1988;39(6):639-645. Not about celiac and GI lymphoma. [pmid: 3243056].
Green Peter H R, Jabri Bana. Celiac disease and other precursors to small-bowel malignancy. Gastroenterol Clin North Am. 2002;31(2):625-639. Review article. [pmid: 12134621].
Green P H R, Jabri B. Coeliac disease. Lancet. 2003;362(9381):383-391. Does not address the question. [pmid: 12907013].
Green P H R, Stavropoulos S N, Panagi S G, et al. Characteristics of adult celiac disease in the USA: results of a national survey. Am J Gastroenterol. 2001;96(1):126-131. Not about celiac and GI lymphoma. [pmid: 11197241].
Gritzmann N, Hollerweger A, Macheiner P, et al. Transabdominal sonography of the gastrointestinal tract. Eur Radiol. 2002;12(7):1748-1761. Not about celiac and GI lymphoma. [pmid: 12695816].
Habeshaw J A, Hayward M J, McVie J G. Extramedullary plasmacytoma of stomach. Scand J Haematol. 1975;14(1):57-64. Not about celiac and GI lymphoma. [pmid: 1121647].
Hadziselimovic F, Emmons L R, Schaub U, et al. Occurrence of large granular lymphocytes and natural killer cells in the epithelium of the gut distinguishes two different coeliac diseases. Gut. 1992;33(6):767-772. Not about celiac and GI lymphoma. [pmid: 1624157]. [pmcid: 1379333].
Halkin H, Meytes D, Militeanu J, et al. Multiple lymphomatous polyposis of the gastrointestinal tract. Isr J Med Sci. 1973;9(5):648-654. Not about celiac and GI lymphoma. [pmid: 4740447].
Hall R P. Dietary management of dermatitis herpetiformis. Arch Dermatol. 1987;123(10):1378a-1380a. Not about celiac and GI lymphoma. [pmid: 3662571].
Halme L, Mecklin J P, Juhola M, et al. Primary gastrointestinal non-Hodgkin's lymphoma. A population based study in central Finland in 1975-1993. Acta Oncol. 1997;36(1):69-74. Does not address the question. [pmid: 9090970].
Hardman C M, Anstey A. The management of dermatitis herpetiformis. J Dermatol Treat. 1998;9(2):125-130. Not about celiac and GI lymphoma.
Harris O D, Cooke W T, Thompson H, et al. Malignancy in adult coeliac disease and idiopathic steatorrhoea. Am J Med. 1967;42(6):899-912. Double publication of included data. [pmid: 5338480].
Harvey Richard F, Shaw Ian S. Current thinking in coeliac disease. Br J Gen Pract. 2002;246(1638):596-602. Not about celiac and GI lymphoma.
Hayat M, Cairns A, Dixon M F, et al. Quantitation of intraepithelial lymphocytes in human duodenum: what is normal?. J Clin Pathol. 2002;55(5):393-394. Not about celiac and GI lymphoma. [pmid: 11986350]. [pmcid: 1769642].
Hekimgil M, Soydan S, Nart D, et al. Histopathologic and immunophenotypic features of childhood and adult anaplastic large-cell lymphomas. Turk J Haematol. 2001;18(4):265-274. Not about celiac and GI lymphoma.
Heneghan M A, Stevens F M, Cryan E M, et al. Celiac sprue and immunodeficiency states: a 25-year review. J Clin Gastroenterol. 1997;25(2):421-425. Not about celiac and GI lymphoma. [pmid: 9412941].
Herron M D, Zone J J. Treatment of dermatitis herpetiformis and linear IgA bullous dermatosis. Dermatol Ther. 2002;15(4):374-381. Not about celiac and GI lymphoma.
Hobbs J R. Immunoflobulins and malabsorption. Proc R Soc Med. 1969;62(10):982-985. Not about celiac and GI lymphoma. [pmid: 4186666]. [pmcid: 1810795].
Hodges J R, Isaacson P, Eade O E, et al. Serum lysozyme levels in malignant histiocytosis of the intestine. Gut. 1979;20(10):854-857. Does not address the question. [pmid: 533696]. [pmcid: 1412725].
Hodges J R, Isaacson P, Smith C L, et al. Malignant histiocytosis of the intestine. Dig Dis Sci. 1979;24(8):631-638. Does not address the question. [pmid: 467214].
Hodgson J R, Hoffman H N, Huizenga K A. Roentgenologic features of lymphoid hyperplasia of the small intestine associated with dysgammaglobulinemia. Radiology. 1967;88(5):883-888. Not about celiac and GI lymphoma. [pmid: 6025045].
Hoffmann M, Vogelsang H, Kletter K, et al. 18F-fluoro-deoxy-glucose positron emission tomography (18F-FDG-PET) for assessment of enteropathy-type T cell lymphoma. Gut. 2003;52(3):347-351. Not about celiac and GI lymphoma. [pmid: 12584214]. [pmcid: 1773540].
Hoggan R. Considering wheat, rye, and barley proteins as aids to carcinogens. Med Hypotheses. 1997;49(3):285-288. Not about celiac and GI lymphoma. [pmid: 9293475].
Holmes G K. Celiac disease and malignancy. J Pediatr Gastroenterol Nutr. 1997;24(5):S20-S23. Review article. [pmid: 9161971].
Holmes G K T. Coeliac disease and malignancy. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(3):229-237. Review article. [pmid: 11990397].
Holmes G K T. Coeliac disease and malignancy. Ann Nestle. 1993;51(2):66-74. Review article.
Holmes G K T. Coeliac disease and Type 1 diabetes mellitus - The case for screening. Diabetic Medicine - a Journal of the British Diabetic Association. 2001;18(3):169-177. Not about celiac and GI lymphoma. [pmid: 11318836].
Holmes G K, Stokes P L, Sorahan T M, et al. Coeliac disease, gluten-free diet, and malignancy. Gut. 1976;17(8):612-619. Double publication of included data. [pmid: 789184]. [pmcid: 1411326].
Hourihane D O, Weir D G. Malignant celiac syndrome. Report of two cases with malabsorption and microscopic foci of intestinal lymphoma. Gastroenterology. 1970;59(1):130-139. Does not address the question. [pmid: 5426983].
Howdle P D, Jalal P K, Holmes G K T, et al. Primary small-bowel malignancy in the UK and its association with coeliac disease. Qjm - Monthly Journal of the Association of Physicians. 2003;96(5):345-353. Does not address the question. [pmid: 12702783].
Howell W M, Jones D B. The role of human leucocyte antigen genes in the development of malignant disease. J Clin Pathol Clin Mol Pathol. 1995;48(6):M302-M306. Not about celiac and GI lymphoma.
Howell W M, Leung S T, Jones D B, et al. HLA-DRB, -DQA, and -DQB polymorphism in celiac disease and enteropathy-associated T-cell lymphoma. Common features and additional risk factors for malignancy. Hum Immunol. 1995;43(1):29-37. Does not address the question. [pmid: 7558926].
Howell W, Martin Calder, Philip C, et al. Gene polymorphisms, inflammatory diseases and cancer. Proc Nutr Soc. 2002;61(4):447-456. Not about celiac and GI lymphoma. [pmid: 12691174].
Ilyas M, Niedobitek G, Agathanggelou A, et al. Non-Hodgkin's lymphoma, coeliac disease, and Epstein-Barr virus: a study of 13 cases of enteropathy-associated T- and B-cell lymphoma. Am J Pathol. 1995;177(2):115-122. Does not address the question.
Isaacson P. Malignant histiocytosis of the intestine: the early histological lesion. Gut. 1980;21(5):381-386. Not about celiac and GI lymphoma. [pmid: 7429300]. [pmcid: 1419099].
Isaacson P. Primary gastrointestinal lymphoma. Virchows Archiv.A. Pathological Anatomy and Histology. 1981;391(1):1-8. Not about celiac and GI lymphoma. [pmid: 7281485].
Isaacson P, Wright D H. Intestinal lymphoma associated with malabsorption. Lancet. 1978;1(8055):67-70. Does not address the question. [pmid: 76907].
Isaacson P, Wright D H. Malignant histiocytosis of the intestine. Its relationship to malabsorption and ulcerative jejunitis. Hum Pathol. 1978;9(6):661-677. Does not address the question. [pmid: 730148].
Isaacson P G. Gastrointestinal lymphoma. Hum Pathol. 1994;25(10):1020-1029. Review article. [pmid: 7927306].
Isaacson P G. Gastrointestinal lymphomas of T- and B-cell types. Modern Pathology - an Official Journal of the United States and Canadian Academy of Pathology, Inc. 1999;12(2):151-158. Review article. [pmid: 10071340].
Isaacson P G. Intestinal lymphoma and enteropathy. Am J Pathol. 1995;177(2):111-113. Review article. [pmid: 7856760].
Isaacson P G. Relation between cryptic intestinal lymphoma and refractory sprue. Lancet. 2000;356(9225):178-179. Does not address the question. [pmid: 10963189].
Isaacson P G. B-cell lymphomas of the gastrointestinal tract. Am J Surg Pathol. 1985;9(3 Suppl):117-128. Not about celiac and GI lymphoma. [pmid: 2416224].
Isaacson P G. T-cell lymphoma: The real thing. Gut. 1999;45(5):638-639. Not about celiac and GI lymphoma. [pmid: 10517893]. [pmcid: 1727717].
Isaacson P, Wright D H, Judd M A, et al. Primary gastrointestinal lymphomas: a classification of 66 cases. Cancer. 1979;43(5):1805-1809. Not about celiac and GI lymphoma. [pmid: 376099].
Jacobsen M B, Fausa O, Elgjo K, et al. Hepatic lesions in adult coeliac disease. Scand J Gastroenterol. 1990;25(7):656-662. Does not address the question. [pmid: 2396080].
James D G, Sharma O P. Overlap syndromes with sarcoidosis. Postgrad Med J. 1985;61(719):769-771. Not about celiac and GI lymphoma. [pmid: 3903708].
James S P. 19. Immunologic, gastroenterologic, and hepatobiliary disorders. J Allergy Clin Immunol. 2003;111(2 Suppl 2):S645-S658. Not about celiac and GI lymphoma. [pmid: 12592310].
Jennings J S R, Howdle P D. Celiac disease. Curr Opin Gastroenterol. 2001;17(2):118-126. Not about celiac and GI lymphoma. [pmid: 11224666].
Johnston S D, Watson R G P. Small bowel lymphoma in unrecognized coeliac disease: A cause for concern?. Eur J Gastroenterol Hepatol. 2000;12(6):645-648. Does not address the question. [pmid: 10912485].
Johnston S D, Watson R G, McMillan S A, et al. Coeliac disease detected by screening is not silent--simply unrecognized. Qjm - Monthly Journal of the Association of Physicians. 1998;91(12):853-860. Not about celiac and GI lymphoma. [pmid: 10024951].
Jones B, Bayless T M, Fishman E K, et al. Lymphadenopathy in celiac disease: computed tomographic observations. Ajr. American Journal of Roentgenology. 1984;142(6):1127-1132. Not about celiac and GI lymphoma. [pmid: 6609595].
Jones D B, Foreman R. Cell origin of lymphoma complicating coeliac disease. Lancet. 1985;2(8463):1067-1068. Not about celiac and GI lymphoma. [pmid: 2865543].
Jones P E, Gleeson M H. Mucosal ulceration and mesenteric lymphadenopathy in coeliac disease. Br Med J. 1973;3(5873):212-213. Not about celiac and GI lymphoma. [pmid: 4753253]. [pmcid: 1586301].
Joshi V V. Pathology of acquired immunodeficiency syndrome (AIDS) in children. Keio J Med. 1996;45(4):306-312. Not about celiac and GI lymphoma. [pmid: 9023448].
Kaerlev L, Teglbjaerg P S, Sabroe S, et al. Medical risk factors for small-bowel adenocarcinoma with focus on Crohn disease: a European population-based case-control study. Scand J Gastroenterol. 2001;36(6):641-646. Not about celiac and GI lymphoma. [pmid: 11424324].
Katoh A, Ohshima K, Kanda M, et al. Gastrointestinal T cell lymphoma: predominant cytotoxic phenotypes, including alpha/beta, gamma/delta T cell and natural killer cells. Leuk lymphoma. 2000;39(12):97-111. Not about celiac and GI lymphoma. [pmid: 10975388].
Katz K D. Celiac Disease - Current Clinical Considerations in Treatment and Avoidance of Nutritional Deficiencies. Today's Ther Trends. 2003;21(4):379-389. Not about celiac and GI lymphoma.
Keating J P. Is celiac disease a premalignant state?. J Pediatr Gastroenterol Nutr. 1984;3(1):4-5. Not about celiac and GI lymphoma. [pmid: 6694046].
Kelly C P, Feighery C F, Gallagher R B et al. Diagnosis and treatment of gluten-sensitive enteropathy. Adv Intern Med 1990;35341–363. Does not address the question
Kepczyk T, Kadakia S C. Prospective evaluation of gastrointestinal tract in patients with iron-deficiency anemia. Dig Dis Sci. 1995;40(6):1283-1289. Not about celiac and GI lymphoma. [pmid: 7781448].
Khilnani M T, Keller R J, Cuttner J. Macroglobulinemia and steatorrhea: roentgen and pathologic findings in the intestinal tract. Radiol Clin North Am. 1969;7(1):43-55. Not about celiac and GI lymphoma. [pmid: 4976485].
Koning F. Celiac disease and malignancy: an immunological basis?. J Pediatr Gastroenterol Nutr. 1997;24(5):S18-S19. Does not address the question. [pmid: 9161970].
Kowlessar O D. Dietary gluten sensitivity updated. J Am Diet Assoc. 1972;60(6):475-477. Not about celiac and GI lymphoma. [pmid: 4556784].
Krawitt E L, Beeken W L. Limitations of the usefulness of the d-xylose absorption test. Am J Clin Pathol. 1975;63(2):261-263. Not about celiac and GI lymphoma. [pmid: 46695].
Krikler D M. Steatorrhoea and plasma-alkaline-phosphatase. Lancet 1968;2(7558):51Not about celiac and GI lymphoma
Kruschwitz M, Fritzsche G, Schwarting R, et al. Ber-ACT8: new monoclonal antibody to the mucosa lymphocyte antigen. J Clin Pathol. 1991;44(8):636-645. Not about celiac and GI lymphoma. [pmid: 1890196]. [pmcid: 496753].
Lahdeaho M-L, Lehtinen T, Aine R, et al. Antibody response to adenovirus E1b-derived synthetic peptides and serum levels of p53 in patients with gastrointestinal and other malignant lymphomas. J Med Virol. 1994;43(4):393-396. Not about celiac and GI lymphoma. [pmid: 7964649].
Lang-Muritano M, Molinari L, Dommann-Scherrer C, et al. Incidence of enteropathy-associated T-cell lymphoma in celiac disease: Implications for children and adolescents with type 1 diabetes. Pediatr Diabetes. 2002;3(1):42-45. Does not address the question. [pmid: 15016174].
Lasch E E, Ramot B, Neumann G. Childhood celiac disease in Israel. Epidemiological aspects. Isr J Med Sci. 1968;4(6):1260-1264. Not about celiac and GI lymphoma. [pmid: 5728813].
Leonard J N, Tucker W F, Fry J S, et al. Increased incidence of malignancy in dermatitis herpetiformis. Br Med J (Clin Res Ed). 1983;286(6358):16-18. Not about celiac and GI lymphoma. [pmid: 6401441].
Levinson J D, Kirsner J B. Infiltrative diseases of the small bowel and malabsorption. Am J Dig Dis. 1970;15(8):741-766. Not about celiac and GI lymphoma. [pmid: 4195473].
Lewin K J, Kahn L B, Novis B H. Primary intestinal lymphoma of “Western” and “Mediterranean” type, alpha chain disease and massive plasma cell infiltration: a comparative study of 37 cases. Cancer. 1976;38(6):2511-2528. Not about celiac and GI lymphoma. [pmid: 826314].
Little A-M, Stern P L. Does HLA type predispose some individuals to cancer?. Mol Med Today. 1999;5(8):337-342. Not about celiac and GI lymphoma. [pmid: 10431166].
Lojda Z. Proteinases in pathology. Usefulness of histochemical methods. Journal of Histochemistry and Cytochemistry - Official Journal of the Histochemistry Society. 1981;29(3a Suppl):481-493. Not about celiac and GI lymphoma.
Luzi G, Zullo A, Iebba F, et al. Duodenal pathology and clinical-immunological implications in common variable immunodeficiency patients. Am J Gastroenterol. 2003;98(1):118-121. Not about celiac and GI lymphoma. [pmid: 12526946].
Machulla H K G, Muller L P, Schaaf A, et al. Association of chronic lymphocytic leukemia with specific alleles of the HLA-DR4:DR53:DQ8 haplotype in German patients. Int J Cancer. 2001;92(2):203-207. Not about celiac and GI lymphoma. [pmid: 11291046].
Maclaurin B P, Cooke W T, Ling N R. Impaired lymphocyte reactivity against tumour cells in patients with coeliac disease. Gut. 1971;12(10):794-800. Not about celiac and GI lymphoma. [pmid: 5171322]. [pmcid: 1411875].
Marsh M N. Studies of intestinal lymphoid tissue. IV--The predictive value of raised mitotic indices among jejunal epithelial lymphocytes in the diagnosis of gluten-sensitive enteropathy. J Clin Pathol. 1982;35(5):517-525. Not about celiac and GI lymphoma. [pmid: 7085895]. [pmcid: 497709].
Marsh M N, Haeney M R. Studies of intestinal lymphoid tissue. VI. Proliferative response of small intestinal epithelial lymphocytes distinguishes gluten-from non-gluten-induced enteropathy. J Clin Pathol. 1983;36(2):149-160. Not about celiac and GI lymphoma. [pmid: 6826770]. [pmcid: 498142].
Marsh M N, Mathan M, Mathan V I. Studies of intestinal lymphoid tissue. VII. The secondary nature of lymphoid cell “activation” in the jejunal lesion of tropical sprue. Am J Pathol. 1983;112(3):302-312. Not about celiac and GI lymphoma. [pmid: 6614143]. [pmcid: 1916392].
Marshak R H, Hazzi C, Lindner A E, et al. The radiology corner: the small bowel in immunoglobulin deficiency syndromes. Am J Gastroenterol. 1975;64(1):59-73. Not about celiac and GI lymphoma. [pmid: 808122].
Marshak R H, Hazzi C, Lindner A E, et al. Small bowel in immunoglobulin deficiency syndromes. Am J Roentgenol Radium Ther Nucl Med. 1974;122(2):227-240. Not about celiac and GI lymphoma. [pmid: 4214044].
Marshak R H, Linder A E, Maklansky D. Immunoglobulin disorders of the small bowel. Radiol Clin North Am. 1976;14(3):477-491. Not about celiac and GI lymphoma. [pmid: 826982].
Marshak R H, Lindner A E, Maklansky D. Lymphoreticular disorders of the gastrointestinal tract: roentgenographic features. Gastrointest Radiol. 1979;4(2):103-120. Not about celiac and GI lymphoma. [pmid: 582310].
Mathus-Vliegen E M. Coeliac disease and lymphoma: current status. Neth J Med. 1996;49(5):212-220. Review article. [pmid: 8973099].
Mathus-Vliegen E M H. Lymphoma in coeliac disease. J R Soc Med. 1995;88(12):672-677. Review article. [pmid: 8786586]. [pmcid: 1295407].
Mathus-Vliegen E M, Van Halteren H, Tytgat G N. Malignant lymphoma in coeliac disease: various manifestations with distinct symptomatology and prognosis?. J Inter Med. 1994;236(1):43-49. Does not address the question.
Maurino Eduardo, Niveloni Sonia, Chernavsky Alejandra, et al. Azathioprine in refractory sprue: results from a prospective, open-label study. Am J Gastroenterol. 2002;97(10):2595-2602. Not about celiac and GI lymphoma. [pmid: 12385445].
Mazzacca G. Diet, coeliac disease and gastrointestinal neoplasm. Adv Exp Med Biol 1993;348133–136. Not about celiac and GI lymphoma
McCrae W M, Eastwood M A, Martin M R, et al. Neglected coeliac disease. Lancet. 1975;1(7900):187-190. Does not address the question. [pmid: 47419].
McElvaney N G, Duignan R, Fielding J F. Coeliac disease: clinical presentations, correlations of dietary compliance, symptomatic response and repeat biopsy findings. Ulster Med J. 1992;61(2):134-138. Does not address the question. [pmid: 1481302].
McPherson J R. Jejunal biopsy. Med Clin North Am. 1970;54(4):851-862. Not about celiac and GI lymphoma. [pmid: 4193250].
McPherson J R. Jejunal biopsy in the diagnosis of malabsorption syndromes. Dis Colon Rectum. 1965;8(6):425-430. Not about celiac and GI lymphoma. [pmid: 4158553].
McPhillips J. Understanding coeliac disease: symptoms and long-term risks. Br J Nurs. 2000;9(8):479-483. Not about celiac and GI lymphoma. [pmid: 11143669].
Mead G M, Whitehouse J M, Thompson J, et al. Clinical features and management of malignant histiocytosis of the intestine. Cancer. 1987;60(11):2791-2796. Does not address the question. [pmid: 3677012].
Mention Jean, Ben Ahmed, Melika Begue, et al. Interleukin 15: a key to disrupted intraepithelial lymphocyte homeostasis and lymphomagenesis in celiac disease. Gastroenterology. 2003;125(3):730-745. Not about celiac and GI lymphoma. [pmid: 12949719].
Michalski J P, McCombs C C. Celiac disease: clinical features and pathogenesis. Am J Med Sci. 1994;307(3):204-211. Not about celiac and GI lymphoma. [pmid: 8160711].
Milovic V, Stein J, Caspary W F. Intestinal malabsorption: Patophysiology, clinical signs and symptoms, diagnosis and treatment (First part). Arch Gastroenterohepatol. 1999;18(34):65-74. Not about celiac and GI lymphoma.
Montgomery R D, Atiyeh M, Scales W R, et al. Intestinal absorption in Saudi Arabia: an evaluation of the one hour blood xylose test. Trans R Soc Trop Med Hyg. 1982;76(1):25-28. Not about celiac and GI lymphoma. [pmid: 7080153].
Morgan D R, Holgate C S, Dixon M F, et al. Primary small intestinal lymphoma: a study of 39 cases. Am J Pathol. 1985;147(3):211-221. Not about celiac and GI lymphoma.
Mulder Chris J J, Hadithi Mohammed M, Rostami Kamran, et al. Coeliac disease--has the time come for routine mass screening? In 2002--2010--2020?. Rom J Gastroenterol. 2002;11(3):179-182. Not about celiac and GI lymphoma. [pmid: 12368936].
Mulder C J, Wahab P J, Moshaver B et al. Refractory coeliac disease: a window between coeliac disease and enteropathy associated T cell lymphoma. Scandinavian Journal of Gastroenterology.Supplement 2000;(232):32–37. Review article
Murray A, Cuevas E C, Jones D B, et al. Study of the immunohistochemistry and T cell clonality of enteropathy-associated T cell lymphoma. Am J Pathol. 1995;146(2):509-519. Not about celiac and GI lymphoma. [pmid: 7856760]. [pmcid: 1869840].
Mussche M, Thienpont L. Adult celiac disease complicated by intestinal reticulum cell sarcoma with high serum IgA level. Acta Clin Belg. 1974;29(6):388-393. Does not address the question. [pmid: 4613099].
Neild G H. Coeliac disease: a graft-versus-host-like reaction localised to the small bowel wall?. Lancet. 1981;1(8224):811-812. Does not address the question. [pmid: 6111675].
Nelsen D A Gluten-sensitive enteropathy (celiac disease): More common than you think. Am Fam Phys 2002;66(12):2259–2266+2269. Not about celiac and GI lymphoma
Nicolas M E O, Krause P K, Gibson L E, et al. Dermatitis herpetiformis. Int J Dermatol. 2003;42(8):588-600. Not about celiac and GI lymphoma. [pmid: 12890100].
Novis B H, Bank S, Marks I N. Gastric acid secretion and intestinal malabsorption. South African Medical Journal. Suid-Afrikaanse Tydskrif Vir Geneeskunde. 1973;47(26):1139-1142. Not about celiac and GI lymphoma. [pmid: 4717657].
Novis B H, Bank S, Marks I N, et al. Abdominal lymphoma presenting with malabsorption. Qjm - Monthly Journal of the Association of Physicians. 1971;40(160):521-540. Does not address the question.
O'Boyle C J, Kerin M J, Feeley K, et al. Primary small intestinal tumours: increased incidence of lymphoma and improved survival. Ann R Coll Surg Engl. 1998;80(5):332-334. Does not address the question. [pmid: 9849332].
O'Connor T M, Cronin C C, Loane J F, et al. Type 1 diabetes mellitus, coeliac disease, and lymphoma: a report of four cases. Diabetic Medicine - a Journal of the British Diabetic Association. 1999;16(7):614-617. Does not address the question. [pmid: 10445840].
O'Driscoll B R, Stevens F M, O'Gorman T A, et al. HLA type of patients with coeliac disease and malignancy in the west of Ireland. Gut. 1982;23(8):662-665. Pathogenesis only. [pmid: 7095561]. [pmcid: 1419133].
O'Farrelly C. Is villous atrophy always and only the result of gluten sensitive disease of the intestine?. Eur J Gastroenterol Hepatol. 2000;12(6):605-608. Not about celiac and GI lymphoma. [pmid: 10912475].
O'Farrelly C, Feighery C, O'Briain D S, et al. Humoral response to wheat protein in patients with coeliac disease and enteropathy associated T cell lymphoma. Br Med J (Clin Res Ed). 1986;293(6552):908-910. Not about celiac and GI lymphoma. [pmid: 3094712].
O'Grady J G, Stevens F M, McCarthy C F. Celiac disease: does hyposplenism predispose to the development of malignant disease?. Am J Gastroenterol. 1985;80(1):27-29. Does not address the question. [pmid: 3966450].
O'Grady J G, Stevens F M, Harding B, et al. Hyposplenism and gluten-sensitive enteropathy. Natural history, incidence, and relationship to diet and small bowel morphology. Gastroenterology. 1984;87(6):1326-1331. Not about celiac and GI lymphoma. [pmid: 6489698].
O'Mahony S, Howdle P D, Losowsky M S. Review article: management of patients with non-responsive coeliac disease. Aliment Pharmacol Ther. 1996;10(5):671-680. Review article. [pmid: 8899074].
O'Malley Martin E, Wilson Stephanie R. US of gastrointestinal tract abnormalities with CT correlation. Radiographics - a Review Publication of the Radiological Society of North America, Inc. 2003;23(1):59-72. Not about celiac and GI lymphoma. [pmid: 12533641].
Oberhuber G. Histopathology of celiac disease. Biomed Pharmacother. 2000;54(7):368-372. Not about celiac and GI lymphoma. [pmid: 10989975].
Otto H F, Bettmann I, Weltzien J V, et al. Primary intestinal lymphomas. Virchows Archiv. A, Pathological Anatomy and Histology. 1981;391(1):9-31. Review article.
Parnell N D, Ciclitira P J. Review article: coeliac disease and its management. Aliment Pharmacol Ther. 1999;13(1):1-13. Not about celiac and GI lymphoma. [pmid: 10383530].
Parry Sally D, Welfare Mark R, Cobden Irving, et al. Push enteroscopy in a UK district general hospital: experience of 51 cases over 2 years. Eur J Gastroenterol Hepatol. 2002;14(3):305-309. Not about celiac and GI lymphoma. [pmid: 11953697].
Patey-Mariaud de, Serre Cellier C, Jabri B, et al. Distinction between coeliac disease and refractory sprue: a simple immunohistochemical method. Histopathology. 2000;37(1):70-77. Not about celiac and GI lymphoma. [pmid: 10931221].
Pearce Allum B, Sinclair David, Duncan Hamish D, et al. Use of the anti-endomysial antibody test to diagnose coeliac disease in clinical practice. Clin Lab. 2002;48(56):319-325. Not about celiac and GI lymphoma. [pmid: 12071583].
Perera D R, Weinstein W M, Rubin C E. Symposium on pathology of the gastrointestinal tract-Part II. Small intestinal biopsy. Hum Pathol. 1975;6(2):157-217. Not about celiac and GI lymphoma. [pmid: 50260].
Peters U, Askling J, Gridley G, et al. Causes of death in patients with celiac disease in a population-based Swedish cohort. Arch Intern Med. 2003;163(13):1566-1572. Double publication of included data. [pmid: 12860579].
Pricolo V E, Mangi A A, Aswad B, et al. Gastrointestinal malignancies in patients with celiac sprue. Am J Surg. 1998;176(4):344-347. Does not address the question. [pmid: 9817252].
Pruessner H T. Detecting celiac disease in your patients. Am Fam Physician 1998;57(5):1023–34, 1039. Not about celiac and GI lymphoma
Purtilo D T, Greally J. Coeliac disease and malignancy. Lancet. 1983;1(8327):771. Not about celiac and GI lymphoma. [pmid: 6132117].
Ramot B, Many A. Primary intestinal lymphoma: clinical manifestations and possible effect of environmental factors. Recent Results in Cancer Research.Fortschritte Der Krebsforschung.Progres Dans Les Recherches Sur Le Cancer 1972;39193–199. Review article
Rampertab S D, Forde K A, Green P H R. Small bowel neoplasia in coeliac disease. Gut. 2003;52(8):1211-1214. Not about celiac and GI lymphoma. [pmid: 12865284]. [pmcid: 1773745].
Read A E. Malignancy and steatorrhea. Bibl Paediatr 1968;87182–190. Not about celiac and GI lymphoma
Reunala T L, Leonard J N. Malignant disease in dermatitis herpetiformis. Clin Dermatol. 1991;9(3):369-373. Not about celiac and GI lymphoma. [pmid: 1806224].
Reunala T, Helin H, Kuokkanen K, et al. Lymphoma in dermatitis herpetiformis: Report of four cases. Acta Derm-Venereol. 1982;62(4):343-346. Not about celiac and GI lymphoma. [pmid: 6183872].
Ricart E, Bouma G, Salvador Pen, et al. The therapeutic spectrum of infliximab and tumor necrosis factor immunomodulation in chronic inflammatory diseases. Drugs Today. 2002;38(11):725-744. Not about celiac and GI lymphoma. [pmid: 12582457].
Risch N. Assessing the role of HLA-linked and unlinked determinants of disease. Am J Hum Genet. 1987;40(1):1-14. Not about celiac and GI lymphoma. [pmid: 3618593]. [pmcid: 1684002].
Robert M E, Ament M E, Weinstein W M. The histologic spectrum and clinical outcome of refractory and unclassified sprue. Am J Surg Pathol. 2000;24(5):676-687. Not about celiac and GI lymphoma. [pmid: 10800986].
Robertson D A F, Dixon M F, Scott B B. Small intestinal ulceration: Diagnostic difficulties in relation to coeliac disease. Gut. 1983;24(6):565-574. Not about celiac and GI lymphoma. [pmid: 6852635]. [pmcid: 1420003].
Robertson D A F, Swinson C M, Hall R, et al. Coeliac disease, splenic function, and malignancy. Gut. 1982;23(8):666-669. Not about celiac and GI lymphoma. [pmid: 7095562]. [pmcid: 1419123].
Rossini F P. Quo vadis capsule endoscopy?. Dig Liver Dis. 2002;34(8):537-539. Not about celiac and GI lymphoma. [pmid: 12502213].
Rowland M, Imrie C, Bourke B, et al. How should Helicobacter pylori infected children be managed?. Gut. 1999;45(Suppl 1):36-39. Not about celiac and GI lymphoma. [pmid: 10457035].
Ruan E A, Komorowski R A, Hogan W J, et al. Nongranulomatous chronic idiopathic enterocolitis: Clinicopathologic profile and response to corticosteroids. Gastroenterology. 1996;111(3):629-637. Not about celiac and GI lymphoma. [pmid: 8780567].
Rubesin S E. Simplified approach to differential diagnosis of small bowel abnormalities. Radiol Clin North Am. 2003;41(2):343-364. Not about celiac and GI lymphoma. [pmid: 14661660].
Rubesin S E, Gilchrist A M, Bronner M, et al. Non-Hodgkin lymphoma of the small intestine. Radiographics - a Review Publication of the Radiological Society of North America, Inc. 1990;10(6):985-998. Review article. [pmid: 2259769].
Rubesin S E, Herlinger H, Saul S H, et al. Adult celiac disease and its complications. Radiographics - a Review Publication of the Radiological Society of North America, Inc. 1989;9(6):1045-1066. Review article. [pmid: 2685933].
Ruskone-Fourmestraux A, Rambaud J C. Gastrointestinal lymphoma: prevention and treatment of early lesions. Best Practice & Research. Clinical Gastroenterology. 2001;15(2):337-354. Review article. [pmid: 11355919].
Ryan B M, Kelleher D. Refractory celiac disease. Gastroenterology. 2000;119(1):243-251. Review article. [pmid: 10889175].
Ryan J C. Premalignant conditions of the small intestine. Semin Gastrointest Dis. 1996;7(2):88-93. Review article. [pmid: 8705262].
Sampson H A. Food allergy. Curr Opin Immunol. 1989;2(4):542-547. Not about celiac and GI lymphoma. [pmid: 2700896].
Sategna-Guidetti C, Grosso S, Bruno M, et al. Comparison of serum anti-gliadin, anti-endomysium, and anti-jejunum antibodies in adult celiac sprue. J Clin Gastroenterol. 1995;20(1):17-21. Not about celiac and GI lymphoma. [pmid: 7884170].
Savilahti E, Ormala T, Saukkonen T, et al. Jejuna of patients with insulin-dependent diabetes mellitus (IDDM) show signs of immune activation. Clin Exp Immunol. 1999;116(1):70-77. Not about celiac and GI lymphoma. [pmid: 10209507]. [pmcid: 1905225].
Schattner A, Kozak N, Lassry Y, et al. Primary intestinal T-cell lymphoma and sclerosing cholangitis: A cytokine-mediated association?. J Intern Med. 1998;244(6):537-541. Not about celiac and GI lymphoma. [pmid: 9893108].
Schmitt-Graff A, Hummel M, Zemlin M, et al. Intestinal T-cell lymphoma: a reassessment of cytomorphological and phenotypic features in relation to patterns of small bowel remodelling. Virchows Archiv - an International Journal of Pathology. 1996;429(1):27-36. Not about celiac and GI lymphoma. [pmid: 8865850].
Schweizer J J, Oren A, Mearin M L. Cancer in children with celiac disease: a survey of the European Society of Paediatric Gastroenterology, Hepatology and Nutrition. J Pediatr Gastroenterol Nutr. 2001;33(1):97-100. Not about celiac and GI lymphoma. [pmid: 11479418].
Scott B B, Losowsky M S. Depressed cell mediated immunity in coeliac disease. Gut. 1976;17(11):900-905. Not about celiac and GI lymphoma. [pmid: 1017719]. [pmcid: 1411220].
Seaman W B, Galdabini J J. Intestinal obstruction complicating adult Celiac disease. New Engl J Med. 1976;295(22):1242-1248. Not about celiac and GI lymphoma. [pmid: 790186].
Sedghizadeh Parish P, Shuler Charles F, Allen Carl M, et al. Celiac disease and recurrent aphthous stomatitis: a report and review of the literature. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2002;94(4):474-478. Not about celiac and GI lymphoma. [pmid: 12374923].
Selby W, Gallagher N D. Development of malignancy in 9 of 96 patients with adult coeliac disease. Aust New Zealand J Med. 1978;8(6):669. Does not address the question.
Seligmann M. Alpha heavy chain disease. Blut. 1975;31(1):1-4. Not about celiac and GI lymphoma. [pmid: 1148399].
Selzer G, Sherman G, Callihan T R, et al. Primary small intestinal lymphomas and alpha-heavy-chain disease. A study of 43 cases from a pathology department in Israel. Isr J Med Sci. 1979;15(2):111-123. Not about celiac and GI lymphoma. [pmid: 112083].
Seraphin Peter, Mobarhan Sohrab. Mortality in patients with celiac disease. Nutr Rev. 2002;60(4):116-118. Review article. [pmid: 12002682].
Shaoul R, Marcon M A, Okada Y, et al. Gastric metaplasia: a frequently overlooked feature of duodenal biopsy specimens in untreated celiac disease. J Pediatr Gastroenterol Nutr. 2000;30(4):397-403. Not about celiac and GI lymphoma. [pmid: 10776950].
Sharma B C, Bhasin D K, Makharia G, et al. Diagnostic value of push-type enteroscopy: A report from India. Am J Gastroenterol. 2000;95(1):137-140. Not about celiac and GI lymphoma. [pmid: 10638572].
Sheldon W. Prognosis in early adult life of coeliac children treated with a gluten-free diet. Br Med J. 1969;2(654):401-404. Not about celiac and GI lymphoma. [pmid: 5781486]. [pmcid: 1983338].
Shepherd N A, Blackshaw A J, Hall P A, et al. Malignant lymphoma with eosinophilia of the gastrointestinal tract. Histopathology. 1987;11(2):115-130. Does not address the question. [pmid: 3570175].
Shils M E. Nutritional problems associated with gastrointestinal and genitourinary cancer. Cancer Res. 1977;37(7 Pt 2):2366-2372. Not about celiac and GI lymphoma. [pmid: 405098].
Shiner M. Present trends in coeliac disease. Postgrad Med J. 1984;60(709):773-778. Not about celiac and GI lymphoma. [pmid: 6390405].
Shiner M, Pearson J R. Abnormalities in the jejunal mucosa in Arab children. Gastroenterol Clin Biol. 1981;5(67):663-673. Not about celiac and GI lymphoma. [pmid: 7250618].
Shreeve D R, Horrocks P, Mainwaring A R. Steatorrhoea and intra-abdominal lymphoma. Scand J Gastroenterol. 1968;3(6):577-585. Does not address the question. [pmid: 4893731].
Signore A, Chianelli M, Annovazzi A, et al. Imaging active lymphocytic infiltration in coeliac disease with iodine-123-interleukin-2 and the response to diet. Eur J Nucl Med. 2000;27(1):18-24. Not about celiac and GI lymphoma. [pmid: 10654142].
Sigurgeirsson B, Agnarsson B A, Lindelof B. Risk of lymphoma in patients with dermatitis herpetiformis. BMJ. 1994;308(6920):13-15. Not about celiac and GI lymphoma. [pmid: 8298344].
Simu G, Jung J, Vojth V, et al. Microscopic observations concerning the autoimmune response escalation into malignant lymphoma. Morphol Embryol (Bucur). 1986;32(2):99-104. Not about celiac and GI lymphoma. [pmid: 2942772].
Sjaastad O. Urinary excretion of free and conjugated histamine in various gastrointestinal disorders. Acta Med Scand. 1969;185(6):495-499. Not about celiac and GI lymphoma. [pmid: 5820146].
Skinner J M. Gastrointestinal lymphoma. Pathology. 1985;17(2):193-203. Review article. [pmid: 3900895].
Skinner J M, Whitehead R. Immunological aspects of gastro-intestinal pathology. Curr Top Pathol 1976;63259–288. Not about celiac and GI lymphoma
Slavutsky I, Gomez J C, Pedreira S, et al. Increased rDNA transcriptional activity in celiac disease. J Clin Gastroenterol. 1992;14(1):11-14. Not about celiac and GI lymphoma. [pmid: 1556401].
Sleisenger M H, Brandborg L L. Malabsorption. Major Probl Intern Med 1977;131–261. Not about celiac and GI lymphoma
Smith E P, Zone J J. Dermatitis herpetiformis and linear IgA bullous dermatosis. Dermatol Clin. 1993;11(3):511-526. Not about celiac and GI lymphoma. [pmid: 8365036].
Sollid L, Bruserud O, Gaudernack G, et al. The role of the CD8-positive subset of T cells in proliferative responses to soluble antigens. I. Studies of healthy subjects, type 1 diabetics, and coeliac disease patients. Scand J Immunol. 1986;23(4):461-467. Not about celiac and GI lymphoma. [pmid: 3010444].
Sorensen H T, Fonager K. Risk estimation of disorders associated with coeliac disease. A 16-year Danish nationwide follow-up study based on hospital discharge data. Implications for screening. Int J Risk Saf Med. 1996;8(2):137-140. Unable to extract data.
Spence W J, Ritchie S. Lymphomas of small bowel and their relationship to idiopathic steatorrhea. Canadian Journal of Surgery. Journal Canadien De Chirurgie. 1969;12(2):207-209. Not about celiac and GI lymphoma. [pmid: 4887681].
Spencer J, Cerf-Bensussan N, Jarry A, et al. Enteropathy-associated T cell lymphoma (malignant histiocytosis of the intestine) is recognized by a monoclonal antibody (HML-1) that defines a membrane molecule on human mucosal lymphocytes. Am J Pathol. 1988;132(1):1-5. Not about celiac and GI lymphoma. [pmid: 3260750]. [pmcid: 1880632].
Spencer J, MacDonald T T, Diss T C, et al. Changes in intraepithelial lymphocyte subpopulations in coeliac disease and enteropathy associated T cell lymphoma (malignant histiocytosis of the intestine). Gut. 1989;30(3):339-346. Not about celiac and GI lymphoma. [pmid: 2785074]. [pmcid: 1378456].
Spiro H M. About this issue. J Clin Gastroenterol. 1995;21(2):81. Not about celiac and GI lymphoma. [pmid: 8648049].
Stazi Maria, Antonietta Cotichini, Rodolfo Patriarca, et al. The Italian Twin Project: from the personal identification number to a national twin registry. Twin Research - the Official Journal of the International Society for Twin Studies. 2002;5(5):382-386. Not about celiac and GI lymphoma. [pmid: 12537863].
Stein E, Shane E. Secondary osteoporosis. Endocrinol Metab Clin North Am. 2003;32(1):115-134. Not about celiac and GI lymphoma. [pmid: 12699295].
Stein H, Dienemann D, Sperling M, et al. Identification of a T cell lymphoma category derived from intestinal-mucosa-associated T cells. Lancet. 1988;2(8619):1053-1054. Not about celiac and GI lymphoma. [pmid: 2903281].
Stenhammar L, Brandt A, Wagermark J. A family study of coeliac disease. Acta Paediatr Scand. 1982;71(4):625-628. Not about celiac and GI lymphoma. [pmid: 7136679].
Stenstam M, Brandt L, Hallberg T. Subnormal response of blood lymphocytes to phytohaemagglutinin in adult coeliac disease complicated by intestinal lymphoma. Scand J Gastroenterol. 1983;18(6):777-781. Not about celiac and GI lymphoma. [pmid: 6608138].
Stewart J. Child coeliacs in adult life. Ir Med J. 1974;67(15):411-414. Not about celiac and GI lymphoma. [pmid: 4412415].
Stokes P L, Holmes G K T. Malignancy. Clin Gastroenterol. 1974;3(1):159-170. Not about celiac and GI lymphoma.
Stokes P L, Asquith P, Waterhouse J H, et al. Malignancy in relatives of patients with adult coeliac disease. Gut. 1972;13(10):836-837. Not about celiac and GI lymphoma. [pmid: 5087074]. [pmcid: 1412477].
Stokes P L, Prior P, Sorahan T M. Malignancy in relatives of patients with coeliac disease. Br J Prev Soc Med. 1976;30(1):17-21. Not about celiac and GI lymphoma. [pmid: 949568].
Swerdlow A J, Whittaker S, Carpenter L M, et al. Mortality and cancer incidence in patients with dermatitis herpetiformis: a cohort study. Br J Dermatol. 1993;129(2):140-144. Not about celiac and GI lymphoma. [pmid: 7654572].
Swinson C M, Hall P J, Bedford P A, et al. HLA antigens in coeliac disease associated with malignancy. Gut. 1983;24(10):925-928. Not about celiac and GI lymphoma. [pmid: 6578173]. [pmcid: 1420156].
Swinson C M, Slavin G, Coles E C, et al. Coeliac disease and malignancy. Lancet. 1983;1(8316):111-115. Not about celiac and GI lymphoma. [pmid: 6129425].
Taggart D P, Imrie C W. A new pattern of histologic predominance and distribution of malignant diseases of the small intestine. Surg Gynecol Obstet. 1987;165(6):515-518. Not about celiac and GI lymphoma. [pmid: 3686317].
Thompson H. Necropsy studies on adult coeliac disease. J Clin Pathol. 1974;27(9):710-721. Not about celiac and GI lymphoma. [pmid: 4531433]. [pmcid: 475446].
Thompson H. Pathology of coeliac disease. Curr Top Pathol 1976;6349–75. Not about celiac and GI lymphoma
Thompson H. The small intestine at autopsy. Clin Gastroenterol. 1974;3(1):171-181. Not about celiac and GI lymphoma. [pmid: 4600389].
Thornquist H, Jacobsen G S, Dahl L B, et al. Coeliac disease and gluten-free diet: a following-up study of fifteen young adults. Ann Nutr Metab. 1993;37(6):295-301. Not about celiac and GI lymphoma. [pmid: 8109888].
Trejdosiewicz L K, Malizia G, Oakes J, et al. Expression of the common acute lymphoblastic leukaemia antigen (CALLA gp100) in the brush border of normal jejunum and jejunum of patients with coeliac disease. J Clin Pathol. 1985;38(9):1002-1006. Not about celiac and GI lymphoma. [pmid: 2931454]. [pmcid: 499349].
Trier J S. Diagnostic value of peroral biopsy of the proximal small intestine. N Engl J Med. 1971;285(26):1470-1473. Not about celiac and GI lymphoma. [pmid: 4107817].
Troncone R, Greco L, Auricchio S. Gluten-sensitive enteropathy. Pediatr Clin North Am. 1996;43(2):355-373. Not about celiac and GI lymphoma. [pmid: 8614605].
Tursi A, Gasbarrini G. Acquired gastric mucosa-associated lymphoid tissue (MALT): a review with special emphasis on association with extragastric diseases and management problems of gastric MALT. J Clin Gastroenterol. 1999;29(2):133-137. Review article. [pmid: 10478872].
Vahedi Kouroche, Mascart Francoise, Mary Jean, et al. Reliability of antitransglutaminase antibodies as predictors of gluten-free diet compliance in adult celiac disease. Am J Gastroenterol. 2003;98(5):1079-1087. Not about celiac and GI lymphoma. [pmid: 12809831].
Verkarre V, Asnafi V, Lecomte T, et al. Refractory coeliac sprue is a diffuse gastrointestinal disease. Gut. 2003;52(2):205-211. Does not address the question. [pmid: 12524401]. [pmcid: 1774980].
Verkarre V, Romana S, Cellier C, et al. Recurrent partial trisomy 1q22–q44 in clonal intraepithelial lymphocytes in refractory celiac sprue. Gastroenterology. 2003;125(1):40-46. Does not address the question. [pmid: 12851869].
Veyrieres M, Baillet P, Hay J M, et al. Factors influencing long-term survival in 100 cases of small intestine primary adenocarcinoma. Am J Surg. 1997;173(3):237-239. Not about celiac and GI lymphoma. [pmid: 9124635].
Wahab P J, Crusius J B A, Meijer J W R, et al. Cyclosporin in the treatment of adults with refractory coeliac disease - An open pilot study. Aliment Pharmacol Ther. 2000;14(6):767-774. Not about celiac and GI lymphoma. [pmid: 10848661].
Wahab P J, Meijer Jos W R, Mulder C J J. Histologic follow-up of people with celiac disease on a gluten-free diet: slow and incomplete recovery. Am J Clin Pathol. 2002;118(3):459-463. Not a controlled study. [pmid: 12219789].
Walker W A, Hong R. Immunology of the gastrointestinal tract. II. Eur J Pediatr. 1973;83(5):711-720. Not about celiac and GI lymphoma.
Walsh S V, Egan L J, Connolly C E, et al. Enteropathy-associated T-cell lymphoma in the West of Ireland: low-frequency of Epstein-Barr virus in these tumors. Modern Pathology - an Official Journal of the United States and Canadian Academy of Pathology, Inc. 1995;8(7):753-757. Does not address the question. [pmid: 8539233].
Wartiovaara J, Tarpila S. Cell contacts and polysomes in irradiated human jejunal mucosa at onset of epithelial repair. Laboratory Investigation: A Journal of Technical Methods and Pathology. 1977;36(6):660-665. Not about celiac and GI lymphoma. [pmid: 865085].
Washington K, Stenzel T T, Buckley R H, et al. Gastrointestinal pathology in patients with common variable immunodeficiency and X-linked agammaglobulinemia. Am J Surg Pathol. 1996;20(10):1240-1252. Not about celiac and GI lymphoma. [pmid: 8827031].
Westergaard H. The sprue syndromes. Am J Med Sci. 1985;290(6):249-262. Not about celiac and GI lymphoma. [pmid: 3909813].
Whitehead R. Primary lymphadenopathy complicating idiopathic steatorrhoea. Gut. 1968;9(5):569-575. Not about celiac and GI lymphoma. [pmid: 4887301]. [pmcid: 1552775].
Whitehead R, Skinner J M. Morphology of the gut associated lymphoid system in health and disease: a review. Pathology. 1978;10(1):3-16. Review article. [pmid: 347360].
Whorwell P J, Alderson M R, Foster K J, et al. Death from ischaemic heart-disease and malignancy in adult patients with coeliac disease. Lancet. 1976;2(7977):113-114. Does not address the question. [pmid: 59182].
Williamson R C, Welch C E, Malt R A. Adenocarcinoma and lymphoma of the small intestine. Distribution and etiologic associations. Ann Surg. 1983;197(2):172-178. Does not address the question. [pmid: 6337568]. [pmcid: 1353105].
Wilson F A, Dietschy J M. Differential diagnostic approach to clinical problems of malabsorption. Gastroenterology. 1971;61(6):911-931. Not about celiac and GI lymphoma. [pmid: 5125690].
Wright D H. Enteropathy associated T cell lymphoma. Cancer Surv 1997;30249–261. Review article
Wright D H. The major complications of coeliac disease. Bailliere's Clinical Gastroenterology. 1995;9(2):351-369. Review article. [pmid: 7549031].
Wright D H. The identification and classification of non-Hodgkin's lymphoma: A review. Diagn Histopathol. 1982;5(2):73-111. Not about celiac and GI lymphoma. [pmid: 7047122].
Wu T T, Hamilton S R. Lymphocytic gastritis: association with etiology and topology. Am J Surg Pathol. 1999;23(2):153-158. Not about celiac and GI lymphoma. [pmid: 9989841].
Young W F, Pringle E M. 110 children with coeliac disease, 1950-1969. Arch Dis Child. 1971;46(248):421-436. Not about celiac and GI lymphoma. [pmid: 5109407].
Zarrabi M H, Rosner F. Middle Eastern intestinal lymphoma: report of a case and review of the literature. Am J Med Sci. 1976;272(1):101-119. Not about celiac and GI lymphoma. [pmid: 786012].
Zoli G, Corazza G R, Parente R, et al. Defective phagocyte activity in adult coeliac disease. Eur J Gastroenterol Hepatol. 1992;4(8):675-678. Not about celiac and GI lymphoma.
Zucca E, Roggero E, Bertoni F, et al. Primary extranodal non-Hodgkin's lymphomas. Part 1: Gastrointestinal, cutaneous and genitourinary lymphomas. Ann Oncol. 1997;8(8):727-737. Not about celiac and GI lymphoma. [pmid: 9332679].

### Objective 4 - Expected Consequences of Testing for CD

Aarbakke J, Schjonsby H. Value of urinary simple phenol and indican determinations in the diagnosis of the stagnant loop syndrome. Scand J Gastroenterol. 1976;11(4):409-414. Not about consequences of testing. [pmid: 935803].
Abdulkarim Ahmad S, Burgart Lawrence J, See Jacalyn, et al. Etiology of nonresponsive celiac disease: results of a systematic approach. Am J Gastroenterol. 2002;97(8):2016-2021. Not about consequences of testing. [pmid: 12190170].
Acalovschi M, Jayanthi V, Probert C S, et al. Management of coeliac disease: a changing diagnostic approach but what value in follow up?. Qual Health Care. 1992;1(1):26-28. Not about consequences of testing. [pmid: 10136825].
Acerini C L, Ahmed M L, Ross K M, et al. Coeliac disease in children and adolescents with IDDM: clinical characteristics and response to gluten-free diet. Diabet Med. 1998;15(1):38-44. Not about consequences of testing. [pmid: 9472862].
Ackerman Z, Eliakim R, Stalnikowicz R, et al. Role of small bowel biopsy in the endoscopic evaluation of adults with iron deficiency anemia. Am J Gastroenterol. 1996;91(10):2099-2102. Not about consequences of testing. [pmid: 8855729].
Adrian T E, Besterman H S, Mallinson C N, et al. Plasma trypsin in chronic pancreatitis and pancreatic adenocarcinoma. Clin Chim Acta. 1979;97(23):205-212. Not about consequences of testing. [pmid: 487604].
Agardh D, Nilsson A, Carlsson A, et al. Tissue transglutaminase autoantibodies and human leucocyte antigen in Down Syndrome patients with coeliac disease. Acta Paediatr. 2002;91(1):34-38. Not about consequences of testing. [pmid: 11883815].
Agardh Daniel, Borulf Stefan, Lernmark Ake, et al. Tissue transglutaminase immunoglobulin isotypes in children with untreated and treated celiac disease. J Pediatr Gastroenterol Nutr. 2003;36(1):77-82. Not about consequences of testing. [pmid: 12500000].
Agreus L, Svardsudd K, Tibblin G, et al. Endomysium antibodies are superior to gliadin antibodies in screening for coeliac disease in patients presenting supposed functional gastrointestinal symptoms. Scand J Prim Health Care. 2000;18(2):105-110. Not about consequences of testing. [pmid: 10944065].
Aine L. Coeliac-type permanent-tooth enamel defects. Ann Med. 1996;28(1):9-12. Not about consequences of testing. [pmid: 8932499].
Akesson B, Floren C H. Use of the triolein breath test for the demonstration of fat malabsorption in coeliac disease. Scand J Gastroenterol. 1984;19(3):307-314. Not about consequences of testing. [pmid: 6740206].
Aktay A N, Lee P C, Kumar V, et al. The prevalence and clinical characteristics of celiac disease in juvenile diabetes in Wisconsin. J Pediatr Gastroenterol Nutr. 2001;33(4):462-465. Not about consequences of testing. [pmid: 11698764].
Al Attas R A. How common is celiac disease in Eastern Saudi Arabia?. Ann Saudi Med. 2002;22(56):315-319. Not about consequences of testing. [pmid: 17146251].
Altuntas B, Filik B, Ensari A, et al. Can zinc deficiency be used as a marker for the diagnosis of celiac disease in Turkish children with short stature?. Pediatr Int. 2000;42(6):682-684. Not about consequences of testing. [pmid: 11192528].
Altuntas B, Kansu A, Ensari A, et al. Celiac disease in Turkish short-statured children and the value of antigliadin antibody in diagnosis. Acta Paediatr Jpn. 1998;40(5):457-460. Not about consequences of testing. [pmid: 9821706].
Amann S T, Josephson S A, Toskes P P. Acid steatocrit: a simple, rapid gravimetric method to determine steatorrhea. Am J Gastroenterol. 1997;92(12):2280-2284. Not about consequences of testing. [pmid: 9399770].
Amara W, Husebekk A. Improved method for serological testing in celiac disease--IgA anti-endomysium antibody test: a comparison between monkey oesophagus and human umbilical cord as substrate in indirect immunofluorescence test. Scand J Clin Lab Invest. 1998;58(7):547-554. Not about consequences of testing. [pmid: 9890337].
Ament M E, Perera D R, Esther L J. Sucrase-isomaltase deficiency-a frequently misdiagnosed disease. Eur J Pediatr. 1973;83(5):721-727. Not about consequences of testing.
Amenta J S. Lipiodol absorption and urinary lodide excretion as a screening test for steatorrhea. Clin Chem. 1969;15(4):295-306. Not about consequences of testing. [pmid: 4305455].
Amin M, Eckhardt T, Kapitza S, et al. Correlation between tissue transglutaminase antibodies and endomysium antibodies as diagnostic markers of coeliac disease. Clin Chim Acta. 1999;282(12):219-225. Not about consequences of testing. [pmid: 10340451].
Ammann R W, Akovbiantz A, Hacki W, et al. Diagnostic value of the fecal chymotrypsin test in pancreatic insufficiency, particularly chronic pancreatitis: correlation with the pancreozymin-secretin test, fecal fat excretion and final clinical diagnosis. Digestion. 1981;21(6):281-289. Not about consequences of testing. [pmid: 7250549].
Ammann R, Kashiwagi H. Pancreatic exocrine insufficiency and proteolytic enzymes in stool. A critical evaluation of a new diagnostic test in various forms of steatorrhea. Helv Med Acta. 1966;33(3):220-228. Not about consequences of testing. [pmid: 5972656].
Anand A C, Elias E, Neuberger J M. End-stage primary biliary cirrhosis in a first generation migrant south Asian population. Eur J Gastroenterol Hepatol. 1996;8(7):663-666. Not about consequences of testing. [pmid: 8853255].
Anand B S, Piris J, Jerrome D W, et al. The timing of histological damage following a single challenge with gluten in treated coeliac disease. Q J Med. 1981;50(197):83-94. Not about consequences of testing. [pmid: 7267970].
Anand B S, Piris J, Truelove S C. The role of various cereals in coeliac disease. Q J Med. 1978;47(185):101-110. Not about consequences of testing. [pmid: 674547].
Anand B S, Truelove S C, Offord R E. Skin test for coeliac disease using a subfraction of gluten. Lancet. 1977;1(8003):118-120. Not about consequences of testing. [pmid: 64652].
Andersson H, Dotevall G, Mobacken H. Malignant mesenteric lymphoma in a patient with dermatitis herpetiformis, hypochlorhydria, and small-bowel abnormalities. Scand J Gastroenterol. 1971;6(5):397-399. Not about consequences of testing. [pmid: 5093527].
Anonymous. A long-term survey of coeliac disease. Med J Aust 1971;2(20):992Not about consequences of testing
Anonymous. American Gastroenterological Association medical position statement: Celiac Sprue. Gastroenterology 2001;120(6):1522–1525. Not about consequences of testing
Anonymous. American Thoracic Society/European Respiratory Society statement: Standards for the diagnosis and management of individuals with alpha-1 antitrypsin deficiency. Am J Respir Crit Care Med 2003;168(7):818–900. Not about consequences of testing
Anonymous. Beyond the iceberg: the present and future of coeliac disease screening. Proceedings of a symposium. Ancona, Italy, 20–21 October 1995. Acta Paediatr 1996; 412(Suppl):1–84. Unable to obtain article
Anonymous. Catch-up growth in celiac disease. Nutr Rev 1973;31(1):13–14. Not about consequences of testing
Anonymous. Celiac disease and how to live with it. Harvard Women's Health Watch 2001;8(9):3–4. Not about consequences of testing
Anonymous. Celiac disease: more than an irritable bowel. Harvard Women's Health Watch 2000;7(11):7Not about consequences of testing
Anonymous. Coeliac disease. Br Med J 1970;4(726):1–2. Not about consequences of testing
Anonymous. HIV-associated enteropathy. Lancet 1989;2(8666):777–778. Not about consequences of testing
Anonymous. Screening for coeliac disease has benefits in Williams syndrome. Arch Dis Child 2002;86(4):275Not about consequences of testing
Anonymous. Small-intestinal morphology in infectious hepatitis. JAMA 1969;209(11):1713–1714. Not about consequences of testing
Anson O, Weizman Z, Zeevi N. Celiac disease: parental knowledge and attitudes of dietary compliance. Pediatrics. 1990;85(1):98-103. Not about consequences of testing. [pmid: 2296499].
Aoun J P, Moukarbel N, Aftimos G. Value of duodenal endoscopic markers of villous atrophy. J Med Liban. 2001;49(6):319-324. Not about consequences of testing. [pmid: 12744633].
Araya M, Mondragon A, Perez-Bravo F, et al. Celiac disease in a Chilean population carrying Amerindian traits. J Pediatr Gastroenterol Nutr. 2000;31(4):381-386. Not about consequences of testing. [pmid: 11045834].
Artan R. Antigliadin antibody measurement as a screening test for childhood coeliac disease. Int Med J. 1998;5(3):209-212. Not about consequences of testing.
Ascher H, Hahn-Zoric M, Hanson L A, et al. Value of serologic markers for clinical diagnosis and population studies of coeliac disease. Scand J Gastroenterol. 1996;31(1):61-67. Not about consequences of testing. [pmid: 8927942].
Ascher H, Lanner A, Kristiansson B. A new laboratory kit for anti-gliadin IgA at diagnosis and follow-up of childhood celiac disease. J Pediatr Gastroenterol Nutr. 1990;10(4):443-450. Not about consequences of testing. [pmid: 2358975].
Ascher H. Paediatric aspects of coeliac disease: old challenges and new ones… Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver 2002;34(3):216–224. Not about consequences of testing
Ashabani A, Abushofa U, Abusrewill S, et al. The prevalence of coeliac disease in Libyan children with type 1 diabetes mellitus. Diabetes Metab Res Rev. 2003;19(1):69-75. Not about consequences of testing. [pmid: 12592646].
Ashabani A, Errabtea H, Shapan A, et al. Serologic markers of untreated celiac disease in Libyan children: antigliadin, antitransglutaminase, antiendomysial, and anticalreticulin antibodies. J Pediatr Gastroenterol Nutr. 2001;33(3):276-282. Not about consequences of testing. [pmid: 11593122].
Auricchio S, Cardelli M, De Ritis G. An in vitro animal model for the study of cereal components toxic in celiac disease. Pediatr Res. 1984;18(12):1372-1378. Not about consequences of testing. [pmid: 6441144].
Auricchio S, Greco L, Troncone R. What is the true prevalence of coeliac disease?. Gastroenterol Int. 1990;3(3):140-142. Not about consequences of testing.
Auricchio S, Mazzacca G, Tosi R, et al. Coeliac disease as a familial condition: Identification of asymptomatic coeliac patients within family groups. Gastroenterol Int. 1988;1(1):25-31. Not about consequences of testing.
Babron M-C, Nilsson S, Adamovic S, et al. Meta and pooled analysis of European coeliac disease data. Eur J Hum Genet. 2003;11(11):828-834. Not about consequences of testing. [pmid: 14571266].
Bagnasco M, Montagna P, De Alessandri A, et al. IgA antiendomysium antibodies in human umbilical cord sections as a screening test in relatives of patients with celiac disease. Allergy. 1997;52(10):1017-1021. Not about consequences of testing. [pmid: 9360755].
Bahia M, Rabello A, Brasileiro Filho G et al. Serum antigliadin antibody levels as a screening criterion before jejunal biopsy indication for celiac disease in a developing country. Brazilian Journal of Medical and Biological Research = Revista Brasileira De Pesquisas Medicas E Biologicas / Sociedade Brasileira De Biofisica …Et Al 2001;34(11):1415–1420. Not about consequences of testing
Bahna S L, Gandhi M D. Milk hypersensitivity. II. Practical aspects of diagnosis, treatment and prevention. Ann Allergy. 1983;50(5):295-301. Not about consequences of testing. [pmid: 6625229].
Bai J C, Andrush A, Matelo G, et al. Fecal fat concentration in the differential diagnosis of steatorrhea. Am J Gastroenterol. 1989;84(1):27-30. Not about consequences of testing. [pmid: 2912027].
Bai J, Moran C, Martinez C, et al. Celiac sprue after surgery of the upper gastrointestinal tract. Report of 10 patients with special attention to diagnosis, clinical behavior, and follow-up. J Clin Gastroenterol. 1991;13(5):521-524. Not about consequences of testing. [pmid: 1744387].
Bailey D S, Freedman A R, Price S C, et al. Early biochemical responses of the small intestine of coeliac patients to wheat gluten. Gut. 1989;30(1):78-85. Not about consequences of testing. [pmid: 2563983]. [pmcid: 1378235].
Baker P G, Barry R E, Read A E. Detection of continuing gluten ingestion in treated coeliac patients. Br Med J. 1975;1(5956):486-488. Not about consequences of testing. [pmid: 1125587]. [pmcid: 1672594].
Balasekaran R, Porter J L, Santa Ana C A, et al. Positive results on tests for steatorrhea in persons consuming olestra potato chips. Ann Intern Med. 2000;132(4):279-282. Not about consequences of testing. [pmid: 10681282].
Baldas V, Tommasini A, Trevisiol C, et al. Development of a novel rapid non-invasive screening test for coeliac disease. Gut. 2000;47(5):628-631. Not about consequences of testing. [pmid: 11034577]. [pmcid: 1728098].
Bamforth J, Murray P J, Roberts A H. Spurious steatorrhoea. Br Med J. 1967;2(553):682. Not about consequences of testing. [pmid: 6024530]. [pmcid: 1842304].
Banks Sara M, Salovey Peter, Greener Susan, et al. The effects of message framing on mammography utilization. Health Psychol. 1995;14(2):178-184. Not about consequences of testing. [pmid: 7789354].
Barakat M H, Ali S M, Badawi A R, et al. Peroral endoscopic duodenal biopsy in infants and children. Acta Paediatr Scand. 1983;72(4):563-569. Not about consequences of testing. [pmid: 6624433].
Barbato M, Miglietta M R, Viola F, et al. Impact of modification of diagnostic techniques and criteria on the presentation of celiac disease in the last 16 years. Observation in Rome. Minerva Pediatr. 1996;48(9):359-363. Not about consequences of testing. [pmid: 8968150].
Bardella M T, Minoli G, Radaelli F, et al. Reevaluation of duodenal endoscopic markers in the diagnosis of celiac disease. Gastrointest Endosc. 2000;51(6):714-716. Not about consequences of testing. [pmid: 10840306].
Bardella M T, Minoli G, Ravizza D, et al. Increased prevalence of celiac disease in patients with dyspepsia. Arch Intern Med. 2000;160(10):1489-1491. Not about consequences of testing. [pmid: 10826463].
Bardella M T, Molteni N, Cesana B, et al. IgA antigliadin antibodies, cellobiose/mannitol sugar test, and carotenemia in the diagnosis of and screening for celiac disease. Am J Gastroenterol. 1991;86(3):309-311. Not about consequences of testing. [pmid: 1900142].
Bardella M T, Trovato C, Cesana B M, et al. Serological markers for coeliac disease: is it time to change?. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2001;33(5):426-431. Not about consequences of testing. [pmid: 11529655].
Bardella M T, Vecchi M, Conte D, et al. Chronic unexplained hypertransaminasemia may be caused by occult celiac disease. Hepatology. 1999;29(3):654-657. Not about consequences of testing. [pmid: 10051464].
Barera G, Bianchi C, Calisti L, et al. Screening of diabetic children for coeliac disease with antigliadin antibodies and HLA typing. Arch Dis Child. 1991;66(4):491-494. Not about consequences of testing. [pmid: 2031607].
Barera G, Bonfanti R, Viscardi M, et al. Occurrence of celiac disease after onset of type 1 diabetes: a 6-year prospective longitudinal study. Pediatrics. 2002;109(5):833-838. Not about consequences of testing. [pmid: 11986443].
Barry R E, Barry R, Ene M D, et al. Fluorescein dilaurate--tubeless test for pancreatic exocrine failure. Lancet. 1982;2(8301):742-744. Not about consequences of testing. [pmid: 6125813].
Barry R E, Morris J S, Read A E. A case of small-intestinal mucosal atrophy. Gut. 1970;11(9):743-747. Not about consequences of testing. [pmid: 5473605]. [pmcid: 1553117].
Barton D M, Baskar V, Kamalakannan D, et al. An assessment of care of paediatric and adolescent patients with diabetes in a large district general hospital. Diabet Med. 2003;20(5):394-398. Not about consequences of testing. [pmid: 12752489].
Basso D, Gallo N, Guariso G, et al. Role of anti-transglutaminase (anti-tTG), anti-gliadin, and anti-endomysium serum antibodies in diagnosing celiac disease: a comparison of four different commercial kits for anti-tTG determination. J Clin Lab Anal. 2001;15(3):112-115. Not about consequences of testing. [pmid: 11344524].
Baur X, Sander I, Posch A, et al. Baker's asthma due to the enzyme xylanase - A new occupational allergen. Clin Exp Allergy. 1998;28(12):1591-1593. Not about consequences of testing. [pmid: 10024232].
Beckett C G, Ciclitira P J. Celiac disase. Curr Opin Gastroenterol. 1997;13(2):107-111. Not about consequences of testing.
Beckett C. A gut issue. Nurs Times 1999;95(8):65–6, 69. Not about consequences of testing
Beers M H, Fink A, Beck J C. Screening recommendations for the elderly. Am J Public Health. 1991;81(9):1131-1140. Not about consequences of testing. [pmid: 1951823]. [pmcid: 1405644].
Bejes C, Marvel M K. Attempting the improbable: Offering colorectal cancer screening to all appropriate patients. Fam Pract Res J. 1992;12(1):83-90. Not about consequences of testing. [pmid: 1549951].
Bell D R. Differential diagnosis of diarrhoea in adults. Br J Gen Pract. 1974;213(1273):47-53. Not about consequences of testing.
Belloni C, Avanzini M A, De Silvestri A et al. No evidence of autoimmunity in 6-year-old children immunized at birth with recombinant hepatitis B vaccine. Pediatrics 2002;110(1 Pt 1):E4Not about consequences of testing
Bengtsson U, Nilsson-Balknas U, Hanson L A, et al. Double blind, placebo controlled food reactions do not correlate to IgE allergy in the diagnosis of staple food related gastrointestinal symptoms. Gut. 1996;39(1):130-135. Not about consequences of testing. [pmid: 8881824]. [pmcid: 1383246].
Benini L, Caliari S, Bonfante F, et al. Fecal fat concentration in the screening of steatorrhea. Digestion. 1992;53(12):94-100. Not about consequences of testing. [pmid: 1289179].
Berg N O, Borulf S, Jakobsson I, et al. How to approach the child suspected of malabsorption. Experience from a prospective investigation of suspected malabsorption in children 1968-1976 in Malmo. Acta Paediatr Scand. 1978;67(4):403-411. Not about consequences of testing. [pmid: 676725].
Berger R, Schmidt G. Evaluation of six anti-gliadin antibody assays. J Immunol Methods. 1996;191(1):77-86. Not about consequences of testing. [pmid: 8642204].
Berrill W T, Eade O E, Fitzpatrick P F. Bird Fancier's lung and jejunal villous atrophy. Lancet. 1975;2(7943):1006-1008. Not about consequences of testing. [pmid: 53495].
Bertele R M, Burgin-Wolff A, Berger R, et al. The fluorescent immunosorbent test for IgG gliadin antibodies and the leucocyte migration inhibition test in coeliac disease; comparison of diagnostic value. Eur J Pediatr. 1985;144(1):58-62. Not about consequences of testing. [pmid: 3926501].
Berti I, Trevisiol C, Tommasini A, et al. Usefulness of screening program for celiac disease in autoimmune thyroiditis. Dig Dis Sci. 2000;45(2):403-406. Not about consequences of testing. [pmid: 10711459].
Beutner E H, Kumar V, Chorzelski Craig T P R M, et al. Screening for celiac disease. New Engl J Med. 1989;320(16):1087-1089. Not about consequences of testing. [pmid: 2927490].
Bhatnagar S, Bhan M K. Serological diagnosis of celiac disease. Indian J Pediatr. 1999;66(1 Suppl):S26-S31. Not about consequences of testing. [pmid: 11132465].
Biagi F, Corazza G R. Defining gluten refractory enteropathy. Eur J Gastroenterol Hepatol. 2001;13(5):561-565. Not about consequences of testing. [pmid: 11396537].
Biagi F, Corazza G R. Tissue transglutaminase antibodies: is sensitivity more important than specificity?. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2001;33(5):401-402. Not about consequences of testing. [pmid: 11785714].
Biagi F, Ellis H J, Parnell N D, et al. A non-toxic analogue of a coeliac-activating gliadin peptide: a basis for immunomodulation?. Aliment Pharmacol Ther. 1999;13(7):945-950. Not about consequences of testing. [pmid: 10383530].
Biagi F, Ellis H J, Yiannakou J Y, et al. Tissue transglutaminase antibodies in celiac disease. Am J Gastroenterol. 1999;94(8):2187-2192. Not about consequences of testing. [pmid: 10445548].
Biagi F, Parnell N D, Ellis H J, et al. Endomysial antibody production is not related to histological damage after in vitro gluten challenge. Eur J Gastroenterol Hepatol. 2000;12(1):57-60. Not about consequences of testing. [pmid: 10656211].
Biagi F, Pezzimenti D, Campanella J, et al. Endomysial and tissue transglutaminase antibodies in coeliac sera: a comparison not influenced by previous serological testing. Scand J Gastroenterol. 2001;36(9):955-958. Not about consequences of testing. [pmid: 11521986].
Bilbao J R, Vitoria Juan C, Ortiz Lourdes, et al. Immunoglobulin G autoantibodies against tissue-transglutaminase. A sensitive, cost-effective assay for the screening of celiac disease. Autoimmunity. 2002;35(4):255-259. Not about consequences of testing. [pmid: 12482193].
Binder H J. Cediac sprue--“unmasking” after vagotomy and hiatal-hernia repair. N Engl J Med. 1970;283(10):520-521. Not about consequences of testing. [pmid: 5454774].
Bischoff S C, Mayer J, Wedemeyer J, et al. Colonoscopic allergen provocation (COLAP): a new diagnostic approach for gastrointestinal food allergy. Gut. 1997;40(6):745-753. Not about consequences of testing. [pmid: 9245928]. [pmcid: 1027199].
Bittinger M, Barnert J, Schmidbaur W, et al. D-xylose hydrogen-breath test as a noninvasive screening test for Coeliac disease. What is the optimum xylose dose?. Rom J Gastroenterol. 1997;6(4):235-238. Not about consequences of testing.
Bjarnason I, MacPherson A, Hollander D. Intestinal permeability: an overview. Gastroenterology. 1995;108(5):1566-1581. Not about consequences of testing. [pmid: 7729650].
Bjarnason I, Peters T J, Veall N. A persistent defect in intestinal permeability in coeliac disease demonstrated by a 51Cr-labelled EDTA absorption test. Lancet. 1983;1(8320):323-325. Not about consequences of testing. [pmid: 6134083].
Blackwell P J, Hill P G, Holmes G K T. Autoantibodies to human tissue transglutaminase: superior predictors of coeliac disease. Scand J Gastroenterol. 2002;37(11):1282-1285. Not about consequences of testing. [pmid: 12465726].
Bodanszky H, Horvath K, Bata A, et al. Hydrogen breath test in small intestinal malabsorption. Acta Paediatr Hung. 1987;28(1):45-49. Not about consequences of testing. [pmid: 3620196].
Bodanszky H, Horvath K, Horn G. The D-xylose test in coeliac disease. Acta Paediatr Hung. 1983;24(1):17-22. Not about consequences of testing. [pmid: 6613572].
Bode S, Gudmand-Hoyer E. Evaluation of the gliadin antibody test for diagnosing coeliac disease. Scand J Gastroenterol. 1994;29(2):148-152. Not about consequences of testing. [pmid: 8171283].
Bode S, Gudmand-Hoyer E. Symptoms and haematologic features in consecutive adult coeliac patients. Scand J Gastroenterol. 1996;31(1):54-60. Not about consequences of testing. [pmid: 8819220].
Bode S, Weile B, Krasilnikoff P A, et al. The diagnostic value of the gliadin antibody test in celiac disease in children: a prospective study. J Pediatr Gastroenterol Nutr. 1993;17(3):260-264. Not about consequences of testing. [pmid: 8271124].
Boldrini R, Biselli R, Bosman C. Chylomicron retention disease--the role of ultrastructural examination in differential diagnosis. Pathol Res Pract. 2001;197(11):753-757. Not about consequences of testing. [pmid: 11770019].
Bonamico M, Ballati G, Mariani P, et al. Screening for coeliac disease: the meaning of low titers of anti-gliadin antibodies (AGA) in non-coeliac children. Eur J Epidemiol. 1997;13(1):55-59. Not about consequences of testing. [pmid: 9062780].
Bonamico M, Bottaro G, Pasquino A M, et al. Celiac disease and turner syndrome. J Pediatr Gastroenterol Nutr. 1998;26(5):496-499. Not about consequences of testing. [pmid: 9586758].
Bonamico M, Mariani P, Danesi H M, et al. Prevalence and clinical picture of celiac disease in italian down syndrome patients: a multicenter study. J Pediatr Gastroenterol Nutr. 2001;33(2):139-143. Not about consequences of testing. [pmid: 11568513].
Bonamico M, Mariani P, Mazzilli M C, et al. Frequency and clinical pattern of celiac disease among siblings of celiac children. J Pediatr Gastroenterol Nutr. 1996;23(2):159-163. Not about consequences of testing. [pmid: 8856583].
Bonamico M, Morellini M, Mariani P, et al. HLA antigens and antigliadin antibodies in coeliac disease. Dis Markers. 1991;9(6):313-317. Not about consequences of testing. [pmid: 1823310].
Bonamico M, Rasore-Quartino A, Mariani P, et al. Down syndrome and coeliac disease: Usefulness of antigliadin and antiendomysium antibodies. Acta Paediatr. 1996;85(12):1503-1505. Not about consequences of testing. [pmid: 9001668].
Bonamico M, Scire G, Mariani P, et al. Short stature as the primary manifestation of monosymptomatic celiac disease. J Pediatr Gastroenterol Nutr. 1992;14(1):12-16. Not about consequences of testing. [pmid: 1573504].
Bonamico M, Tiberti C, Picarelli A, et al. Radioimmunoassay to detect antitransglutaminase autoantibodies is the most sensitive and specific screening method for celiac disease. Am J Gastroenterol. 2001;96(5):1536-1540. Not about consequences of testing. [pmid: 11374695].
Bonamico Margherita, Pasquino Anna M, Mariani Paolo, et al. Prevalence and clinical picture of celiac disease in Turner syndrome. J Clin Endocrinol Metab. 2002;87(12):5495-5498. Not about consequences of testing. [pmid: 12466343].
Bontems P, Deprettere A, Cadranel S, et al. The coeliac iceberg: a consensus in paediatrics. Acta Gastroenterol Belg. 2000;63(2):157-162. Review article. [pmid: 10925451].
Book L, Hart A, Black J, et al. Prevalence and clinical characteristics of celiac disease in Downs syndrome in a US study. Am J Med Genet. 2001;98(1):70-74. Not about consequences of testing. [pmid: 11426458].
Book Linda, Zone John J, Neuhausen Susan L. Prevalence of celiac disease among relatives of sib pairs with celiac disease in U.S. families. Am J Gastroenterol. 2003;98(2):377-381. Not about consequences of testing. [pmid: 12591058].
Book L S. Diagnosing celiac disease in 2002: who, why, and how?. Pediatrics. 2002;109(5):952-954. Not about consequences of testing. [pmid: 11986459].
Booth S N, King J P G, Leonard J C, et al. The significance of elevation of serum carcinoembryonic antigen (CEA) levels in inflammatory diseases of the intestine. Scand J Gastroenterol. 1974;9(7):651-656. Not about consequences of testing. [pmid: 4428176].
Bostick Roberd M, Sprafka J, Michael Virnig, et al. Predictors of cancer prevention attitudes and participation in cancer screening examinations. Am J Prev Med. 1994;23(6):816-826. Not about consequences of testing.
Bottaro G, Cataldo F, Rotolo N, et al. The clinical pattern of subclinical/silent celiac disease: an analysis on 1026 consecutive cases. Am J Gastroenterol. 1999;94(3):691-696. Not about consequences of testing. [pmid: 10086653].
Bottaro G, Failla P, Rotolo N, et al. Changes in coeliac disease behaviour over the years. Acta Paediatr. 1993;82(67):566-568. Not about consequences of testing. [pmid: 8338991].
Boudraa G, Hachelaf W, Benbouabdellah M, et al. Prevalence of coeliac disease in diabetic children and their first- degree relatives in west Algeria: screening with serological markers. Acta Paediatr. 1996;412(Suppl):58-60. Not about consequences of testing.
Bradlow B A, Haggan J M. A comparison of the plasma viscosity and the erythrocyte sedimentation rate as screening tests. S Afr Med J. 1979;55(11):415-420. Not about consequences of testing. [pmid: 432746].
Bramble M G, Zucoloto S, Wright N A, et al. Acute gluten challenge in treated adult coeliac disease: a morphometric and enzymatic study. Gut. 1985;26(2):169-174. Not about consequences of testing. [pmid: 3917964]. [pmcid: 1432436].
Brett P M, Yiannakou J Y, Morris M A, et al. A pedigree-based linkage study of coeliac disease: failure to replicate previous positive findings. Ann Hum Genet. 1998;62(Pt 1):25-32. Not about consequences of testing. [pmid: 9659975].
Brett P M, Yiannakou J Y, Morris M A, et al. Common HLA alleles, rather than rare mutants, confer susceptibility to coeliac disease. Ann Hum Genet. 1999;63(Pt 3):217-225. Not about consequences of testing. [pmid: 10738534].
Brocchi E, Tomassetti P, Misitano B, et al. Endoscopic markers in adult coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(3):177-182. Not about consequences of testing. [pmid: 11990389].
Brooklyn Trevor N, Di Mambro, Alexandra J, et al. Patients over 45 years with iron deficiency require investigation. Eur J Gastroenterol Hepatol. 2003;15(5):535-538. Not about consequences of testing. [pmid: 12702912].
Brusco G, Di Stefano M, Corazza G R. Increased red cell distribution width and coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2000;32(2):128-130. Not about consequences of testing. [pmid: 10975787].
Brusco G, Izzi L, Corazza G R. Tissue transglutaminase antibodies for coeliac disease screening. Ital J Gastroenterol Hepatol. 1998;30(5):496-497. Not about consequences of testing. [pmid: 9836104].
Bulpitt C J, Benos A S, Nicholl C G, et al. Should medical screening of the elderly population be promoted?. Gerontology. 1990;36(4):230-245. Not about consequences of testing. [pmid: 2272526].
Bundek Nancy I, Marks Gary, Richardson Jean L. Role of health locus of control beliefs in cancer screening of elderly Hispanic women. Health Psychol. 1993;12(3):193-199. Not about consequences of testing. [pmid: 8500448].
Burgin-Wolff A, Berger R, Gaze H, et al. IgG, IgA and IgE gliadin antibody determinations as screening test for untreated coeliac disease in children, a multicentre study. Eur J Pediatr. 1989;148(6):496-502. Not about consequences of testing. [pmid: 2663505].
Burgin-Wolff A, Bertele R M, Berger R, et al. A reliable screening test for childhood celiac disease: fluorescent immunosorbent test for gliadin antibodies. A prospective multicenter study. Eur J Pediatr. 1983;102(5):655-660. Not about consequences of testing.
Burgin-Wolff A, Dahlbom I, Hadziselimovic F, et al. Antibodies against human tissue transglutaminase and endomysium in diagnosing and monitoring coeliac disease. Scand J Gastroenterol. 2002;37(6):685-691. Not about consequences of testing. [pmid: 12126247].
Burgin-Wolff A, Hernandez R, Just M, et al. Immunofluorescent antibodies against gliadin: a screening test for coeliac disease. Helv Paediatr Acta. 1976;31(45):375-380. Not about consequences of testing. [pmid: 797680].
Burks A W, James J M, Hiegel A, et al. Atopic dermatitis and food hypersensitivity reactions. Eur J Pediatr. 1998;132(1):132-136. Not about consequences of testing.
Bushara K O, Goebel S U, Shill H, et al. Gluten sensitivity in sporadic and hereditary cerebellar ataxia. Ann Neurol. 2001;49(4):540-543. Not about consequences of testing. [pmid: 11310636].
Buts J P, Morin C L, Roy C C, et al. One-hour blood xylose test: a reliable index of small bowel function. Eur J Pediatr. 1978;92(5):729-733. Not about consequences of testing.
Caffarelli C, Romanini E, Caruana P, et al. Clinical food hypersensitivity: the relevance of duodenal immunoglobulin E-positive cells. Pediatr Res. 1998;44(4):485-490. Not about consequences of testing. [pmid: 9773835].
Calabuig M, Torregosa R, Polo P, et al. Serological markers and celiac disease: a new diagnostic approach?. J Pediatr Gastroenterol Nutr. 1990;10(4):435-442. Not about consequences of testing. [pmid: 2193137].
Calero P, Ribes-Koninckx C, Albiach V, et al. IgA antigliadin antibodies as a screening method for nonovert celiac disease in children with insulin-dependent diabetes mellitus. J Pediatr Gastroenterol Nutr. 1996;23(1):29-33. Not about consequences of testing. [pmid: 8811520].
Calkhoven P G, Aalbers M, Koshte V L, et al. Relationship between IgGinf 1 and IgGinf 4 antibodies to foods and the development of IgE antibodies to inhalant allergens. I. Establishment of a scoring system for the overall food responsiveness and its application to 213 unselected children. Clin Exp Allergy. 1991;21(1):91-98. Not about consequences of testing. [pmid: 2021885].
Camarero C, Eiras P, Asensio A, et al. Intraepithelial lymphocytes and coeliac disease: permanent changes in CD3-/CD7+ and T cell receptor gammadelta subsets studied by flow cytometry. Acta Paediatr. 2000;89(3):285-290. Not about consequences of testing. [pmid: 10772275].
Campbell C B, Roberts R K, Cowen A E. The changing clinical presentation of coeliac disease in adults. Med J Aust. 1977;1(4):89-93. Not about consequences of testing. [pmid: 557720].
Carlsson A K, Axelsson I E, Borulf S K, et al. Prevalence of IgA-antiendomysium and IgA-antigliadin autoantibodies at diagnosis of insulin-dependent diabetes mellitus in Swedish children and adolescents. Pediatrics. 1999;103(6 Pt 1):1248-1252. Not about consequences of testing. [pmid: 10353937].
Carlsson A K, Axelsson I E, Borulf S K, et al. Serological screening for celiac disease in healthy 2. 5-year-old children in Sweden. Pediatrics. 2001;107(1):42-45. Not about consequences of testing. [pmid: 11134432].
Carlsson A, Axelsson I, Borulf S, et al. Prevalence of IgA-antigliadin antibodies and IgA-antiendomysium antibodies related to celiac disease in children with Down syndrome. Pediatrics. 1998;101(2):272-275. Not about consequences of testing. [pmid: 9445503].
Carnicer J, Farre C, Varea V, et al. Prevalence of coeliac disease in Down Syndrome. Eur J Gastroenterol Hepatol. 2001;13(3):263-267. Not about consequences of testing. [pmid: 11293446].
Carroccio A, Cavataio F, Iacono G, et al. IgA antiendomysial antibodies on the umbilical cord in diagnosing celiac disease. Sensitivity, specificity, and comparative evaluation with the traditional kit. Scand J Gastroenterol. 1996;31(8):759-763. Not about consequences of testing. [pmid: 8858743].
Carroccio A, Custro N, Montalto G, et al. Evidence of transient IgA anti-endomysial antibody positivity in a patient with Graves' disease. Digestion. 1999;60(1):86-88. Not about consequences of testing. [pmid: 9892805].
Carroccio A, Fabiani E, Iannitto E, et al. Tissue transglutaminase autoantibodies in patients with non-Hodgkin's lymphoma: Case reports. Digestion. 2000;62(4):271-275. Not about consequences of testing. [pmid: 11070411].
Carroccio A, Giannitrapani L, Soresi M, et al. Guinea pig transglutaminase immunolinked assay does not predict coeliac disease in patients with chronic liver disease. Gut. 2001;49(4):506-511. Not about consequences of testing. [pmid: 11559647]. [pmcid: 1728470].
Carroccio A, Iacono G, D'Amico D, et al. Production of anti-endomysial antibodies in cultured duodenal mucosa: usefulness in coeliac disease diagnosis. Scand J Gastroenterol. 2002;37(1):32-38. Not about consequences of testing. [pmid: 11843032].
Carroccio A, Iacono G, Ippolito S, et al. Usefulness of faecal elastase-1 assay in monitoring pancreatic function in childhood coeliac disease. Ital J Gastroenterol Hepatol. 1998;30(5):500-504. Not about consequences of testing. [pmid: 9836106].
Carroccio A, Iacono G, Montalto G, et al. Immunologic and absorptive tests in celiac disease: can they replace intestinal biopsies?. Scand J Gastroenterol. 1993;28(8):673-676. Not about consequences of testing. [pmid: 8210980].
Carroccio A, Iannitto E, Cavataio F, et al. Sideropenic anemia and celiac disease: one study, two points of view. Dig Dis Sci. 1998;43(3):673-678. Not about consequences of testing. [pmid: 9539667].
Carroccio Antonio, Iannitto Emilio, Di Prima, et al. Screening for celiac disease in non-Hodgkin's lymphoma patients: a serum anti-transglutaminase-based approach. Dig Dis Sci. 2003;48(8):1530-1536. Not about consequences of testing. [pmid: 12924648].
Carroccio Antonio, Vitale Giustina, Di Prima, et al. Comparison of anti-transglutaminase ELISAs and an anti-endomysial antibody assay in the diagnosis of celiac disease: a prospective study. Clin Chem. 2002;48(9):1546-1550. Not about consequences of testing. [pmid: 12194932].
Carroll Jerome F X, McGinley John J. Managing MICA clients in a modified therapeutic community with enhanced staffing. J Subst Abuse Treat. 1998;15(6):565-577. Not about consequences of testing. [pmid: 9845870].
Carswell F, Ferguson A. Food antibodies in serum--a screening test for coeliac disease. Arch Dis Child. 1972;47(254):594-596. Not about consequences of testing. [pmid: 5065303].
Casellas F, de Torres I, Malagelada J R. Improved screening for intestinal villous atrophy by D-xylose breath test. Dig Dis Sci. 2000;45(1):18-22. Not about consequences of testing. [pmid: 10695607].
Casellas F, Sardi J, de Torres I, et al. Hydrogen breath test with D-xylose for celiac disease screening is as useful in the elderly as in other age groups. Dig Dis Sci. 2001;46(10):2201-2205. Not about consequences of testing. [pmid: 11680597].
Castellano Penny Z, Wenger Nanette K, Graves William L. Adherence to screening guidelines for breast and cervical cancer in postmenopausal women with coronary heart disease: An ancillary study of volunteers for HERS. Journal of Women's Health & Gender-Based Medicine. 2001;10(5):451-461. Not about consequences of testing. [pmid: 11445044].
Castellino F, Scaglione N, Grosso S B, et al. A novel method for detecting IgA endomysial antibodies by using human umbilical vein endothelial cells. Eur J Gastroenterol Hepatol. 2000;12(1):45-49. Not about consequences of testing. [pmid: 10656209].
Cataldo F, Lio D, Marino V, et al. IgG(1) antiendomysium and IgG antitissue transglutaminase (anti-tTG) antibodies in coeliac patients with selective IgA deficiency. Working Groups on Celiac Disease of SIGEP and Club del Tenue. Gut. 2000;47(3):366-369. Not about consequences of testing. [pmid: 10940273]. [pmcid: 1728054].
Cataldo F, Marino V, Bottaro G, et al. Celiac disease and selective immunoglobulin A deficiency. Eur J Pediatr. 1997;131(2):306-308. Not about consequences of testing.
Cataldo F, Marino V, Ventura A, et al. Prevalence and clinical features of selective immunoglobulin A deficiency in coeliac disease: an Italian multicentre study. Italian Society of Paediatric Gastroenterology and Hepatology (SIGEP) and “Club del Tenue” Working Groups on Coeliac Disease. Gut. 1998;42(3):362-365. Not about consequences of testing. [pmid: 9577342]. [pmcid: 1727042].
Cataldo F, Ventura A, Lazzari R, et al. Antiendomysium antibodies and coeliac disease: solved and unsolved questions. An Italian multicentre study. Acta Paediatr. 1995;84(10):1125-1131. Not about consequences of testing. [pmid: 8563223].
Cataldo Francesco, Marino Vincenzo. Increased prevalence of autoimmune diseases in first-degree relatives of patients with celiac disease. J Pediatr Gastroenterol Nutr. 2003;36(4):470-473. Not about consequences of testing. [pmid: 12658037].
Catapani W R, da Silva A N, de Morais M B, et al. Clinical usefulness of acid steatocrit in pediatric practice. Arq Gastroenterol. 1999;36(2):105-108. Not about consequences of testing. [pmid: 10511891].
Catassi C, Fabiani E, Gasparin M, et al. Quantitative antigliadin antibody measurement in clinical practice: an Italian multicentre study. SIGEP Working Group on Quantitative AGA Standardization. Ital J Gastroenterol Hepatol. 1999;31(5):366-370. Not about consequences of testing. [pmid: 10470593].
Catassi C, Fabiani E, Ratsch I M, et al. Celiac disease in the general population: should we treat asymptomatic cases?. J Pediatr Gastroenterol Nutr. 1997;24(5):S10-S12. Not about consequences of testing. [pmid: 9161968].
Catassi C, Fabiani E, Ratsch I M, et al. Is the sugar intestinal permeability test a reliable investigation for coeliac disease screening?. Gut. 1997;40(2):215-217. Not about consequences of testing. [pmid: 9071934]. [pmcid: 1027051].
Catassi C Fabiani E Ratsch I MThe coeliac iceberg in Italy. A multicentre antigliadin antibodies screening for coeliac disease in school-age subjects Acta Paediatr 1996 412 Suppl 29 35Not about consequences of testing
Catassi C, Fabiani E. The spectrum of coeliac disease in children. Bailliere's Clinical Gastroenterology. 1997;11(3):485-507. Not about consequences of testing. [pmid: 9448912].
Catassi C, Fanciulli G, D'Appello A R, et al. Antiendomysium versus antigliadin antibodies in screening the general population for coeliac disease. Scand J Gastroenterol. 2000;35(7):732-736. Not about consequences of testing. [pmid: 10972177].
Catassi C, Fornaroli F, Fasano A. Celiac disease: From basic immunology to bedside practice. Clin Appl Immunol Rev. 2002;3(12):61-71. Not about consequences of testing.
Catassi C, Ratsch I M, Fabiani E, et al. Coeliac disease in the year 2000: exploring the iceberg. Lancet. 1994;343(8891):200-203. Not about consequences of testing. [pmid: 7904667].
Catassi C, Ratsch I M, Fabiani E, et al. High prevalence of undiagnosed coeliac disease in 5280 Italian students screened by antigliadin antibodies. Acta Paediatr. 1995;84(6):672-676. Not about consequences of testing. [pmid: 7670254].
Catassi C, Rossini M, Ratsch I M, et al. Dose dependent effects of protracted ingestion of small amounts of gliadin in coeliac disease children: a clinical and jejunal morphometric study. Gut. 1993;34(11):1515-1519. Not about consequences of testing. [pmid: 8244135]. [pmcid: 1374413].
Catassi Carlo, Fabiani Elisabetta, Corrao Giovanni, et al. Risk of non-Hodgkin lymphoma in celiac disease. JAMA. 2002;287(11):1413-1419. Not about consequences of testing. [pmid: 11903028].
Catino M, Tumini S, Mezzetti A, et al. Coeliac disease and diabetes mellitus in children: A non casual association. Diabetes Nutr Metab Clin Exp. 1998;11(5):296-302. Not about consequences of testing.
Cellier C, Cuillerier E, Patey-Mariaud de, et al. Push enteroscopy in celiac sprue and refractory sprue. Gastrointest Endosc. 1999;50(5):613-617. Not about consequences of testing. [pmid: 10536314].
Cellier C, Delabesse E, Helmer C, et al. Refractory sprue, coeliac disease, and enteropathy-associated T-cell lymphoma. French Coeliac Disease Study Group. Lancet. 2000;356(9225):203-208. Not about consequences of testing. [pmid: 10963198].
Chadwick V S, Phillips S F, Hofmann A F. Measurements of intestinal permeability using low molecular weight polyethylene glycols (PEG 400). II. Application to normal and abnormal permeability states in man and animals. Gastroenterology. 1977;73(2):247-251. Not about consequences of testing. [pmid: 873125].
Challacombe D N. Screening tests for coeliac disease. Arch Dis Child. 1995;73(1):3-4. Not about consequences of testing. [pmid: 7639545].
Challacombe D. When is a coeliac?. Lancet. 1994;343(8891):188. Not about consequences of testing. [pmid: 7993454].
Chambers Ruth. The effectiveness of lifestyle-related health screening: A 2 year follow-up study of doctors and teachers. Fam Pract. 1992;9(4):500-505. Not about consequences of testing. [pmid: 1490546].
Chan A W, Butzner J D, McKenna R, et al. Tissue transglutaminase enzyme-linked immunosorbent assay as a screening test for celiac disease in pediatric patients. Pediatrics. 2001;107(1):E8. Not about consequences of testing. [pmid: 11134472].
Chan K N, Phillips A D, Mirakian R, et al. Endomysial antibody screening in children. J Pediatr Gastroenterol Nutr. 1994;18(3):316-320. Not about consequences of testing. [pmid: 8057214].
Chapman B A, Pattinson N R, Cook H B, et al. Skin testing for coeliac disease. N Z Med J. 1979;90(649):463-464. Not about consequences of testing. [pmid: 294523].
Chartrand L J, Agulnik J, Vanounou T, et al. Effectiveness of antigliadin antibodies as a screening test for celiac disease in children. Cmaj - Canadian Medical Association Journal = Journal De L'association Medicale Canadienne. 1997;157(5):527-533. Not about consequences of testing.
Chartrand L J, Russo P A, Duhaime A G, et al. Wheat starch intolerance in patients with celiac disease. J Am Diet Assoc. 1997;97(6):612-618. Not about consequences of testing. [pmid: 9183321].
Chatzicostas Costantinos, Roussomoustakaki Maria, Drygiannakis Dimitrios, et al. Primary biliary cirrhosis and autoimmune cholangitis are not associated with coeliac disease in Crete. Bmc Gastroenterology Electronic Resource. 2002;2(1):5. Not about consequences of testing. [pmid: 11914139]. [pmcid: 102761].
Cheung Bruno M H, Jeng Kee-Ching G, Lau Yen. Screening for diseases in elderly persons: The correlation between physical checkup findings and chief complaints. Gerontology. 1999;45(5):283-288. Not about consequences of testing. [pmid: 10460991].
Chimenti C, Pieroni M, Frustaci A. Celiac disease in idiopathic dilated cardiomyopathy. Ital Heart J. 2001;2(9):658-659. Not about consequences of testing. [pmid: 11666093].
Chirdo F G, Rumbo M, Carabajal P, et al. Analysis of anti-gliadin antibodies by immunoblot analysis and enzyme-linked immunosorbent assay using gliadin fractions as antigens. J Pediatr Gastroenterol Nutr. 1999;29(2):171-177. Not about consequences of testing. [pmid: 10435654].
Chirdo F G, Rumbo M, Carabajal P, et al. Determination of anti-omega-gliadin antibodies in serologic tests for coeliac disease. Scand J Gastroenterol. 2000;35(5):508-516. Not about consequences of testing. [pmid: 10868454].
Ciacci C, Cavallaro R, Romano R, et al. Increased risk of surgery in undiagnosed celiac disease. Dig Dis Sci. 2001;46(10):2206-2208. Not about consequences of testing. [pmid: 11680598].
Ciacci C, Cirillo M, Cavallaro R, et al. Long-term follow-up of celiac adults on gluten-free diet: prevalence and correlates of intestinal damage. Digestion. 2002;66(3):178-185. Not about consequences of testing. [pmid: 12481164].
Ciacci C, Cirillo M, Giorgetti G, et al. Low plasma cholesterol: a correlate of nondiagnosed celiac disease in adults with hypochromic anemia. Am J Gastroenterol. 1999;94(7):1888-1891. Not about consequences of testing. [pmid: 10406254].
Ciacci C, De Rosa A, De Michele G, et al. Sexual behaviour in untreated and treated coeliac patients. Eur J Gastroenterol Hepatol. 1998;10(8):649-651. Not about consequences of testing. [pmid: 9744692].
Ciacci C, Iavarone A, Siniscalchi M, et al. Psychological dimensions of celiac disease: toward an integrated approach. Dig Dis Sci. 2002;47(9):2082-2087. Not about consequences of testing. [pmid: 12353859].
Ciclitira P J, Ellis H J. In vivo gluten ingestion in coeliac disease. Dig Dis. 1998;16(6):337-340. Not about consequences of testing. [pmid: 10207218].
Ciclitira Paul J. Recent advances in coeliac disease. Clin Med. 2003;3(2):166-169. Not about consequences of testing. [pmid: 12737376].
Clasen Carla M, Vernon Sally W, Mullen Patricia D, et al. A survey of physician beliefs and self-reported practices concerning screening for early detection of cancer. Soc Sci Med. 1994;39(6):841-849. Not about consequences of testing. [pmid: 7973880].
Cleghorn G, Benjamin L, Corey M, et al. Serum immunoreactive pancreatic lipase and cationic trypsinogen for the assessment of exocrine pancreatic function in older patients with cystic fibrosis. Pediatrics. 1986;77(3):301-306. Not about consequences of testing. [pmid: 3951910].
Clemente Maria, Grazia Musu, Maria Paola, et al. Antitissue transglutaminase antibodies outside celiac disease. J Pediatr Gastroenterol Nutr. 2002;34(1):31-34. Not about consequences of testing. [pmid: 11753161].
Cobden I, Hamilton I, Rothwell J, et al. Cellobiose/mannitol test: physiological properties of probe molecules and influence of extraneous factors. Clin Chim Acta. 1985;148(1):53-62. Not about consequences of testing. [pmid: 3924445].
Cobden I, Rothwell J, Axon A T. Intestinal permeability and screening tests for coeliac disease. Gut. 1980;21(6):512-518. Not about consequences of testing. [pmid: 6776013]. [pmcid: 1419649].
Cockburn Jill, Murphy Barbara, Schofield Penelope, et al. Development of a strategy to encourage attendance for screening mammography. Health Educ Res. 1991;6(3):279-290. Not about consequences of testing. [pmid: 10148693].
Cogulu O, Ozkinay F, Gunduz C, et al. Celiac disease in children with down syndrome: Importance of follow-up and serologic screening. Pediatr Int. 2003;45(4):395-399. Not about consequences of testing. [pmid: 12911473].
Colaco J, Egan-Mitchell B, Stevens F M, et al. Compliance with gluten free diet in coeliac disease. Arch Dis Child. 1987;62(7):706-708. Not about consequences of testing. [pmid: 3632017].
Collin P, Hallstrom O, Maki M, et al. Atypical coeliac disease found with serologic screening. Scand J Gastroenterol. 1990;25(3):245-250. Not about consequences of testing. [pmid: 2320942].
Collin P, Helin H, Maki M, et al. Follow-up of patients positive in reticulin and gliadin antibody tests with normal small-bowel biopsy findings. Scand J Gastroenterol. 1993;28(7):595-598. Not about consequences of testing. [pmid: 8362211].
Collin P, Kaukinen K, Maki M. Clinical features of celiac disease today. Dig Dis. 1999;17(2):100-106. Not about consequences of testing. [pmid: 10545715].
Collin P, Korpela M, Hallstrom O, et al. Rheumatic complaints as a presenting symptom in patients with coeliac disease. Scand J Rheumatol. 1992;21(1):20-23. Not about consequences of testing. [pmid: 1570482].
Collin P, Maki M. Associated disorders in coeliac disease: clinical aspects. Scand J Gastroenterol. 1994;29(9):769-775. Not about consequences of testing. [pmid: 7824853].
Collin P, Rasmussen M, Kyronpalo S, et al. The hunt for coeliac disease in primary care. QJM. 2002;95(2):75-77. Not about consequences of testing. [pmid: 11861953].
Collin P, Reunala T, Rasmussen M, et al. High incidence and prevalence of adult coeliac disease. Augmented diagnostic approach. Scand J Gastroenterol. 1997;32(11):1129-1133. Not about consequences of testing. [pmid: 9399394].
Collin P, Salmi J, Hallstrom O, et al. Autoimmune thyroid disorders and coeliac disease. Eur J Endocrinol. 1994;130(2):137-140. Not about consequences of testing. [pmid: 8130887].
Collin P, Salmi J, Hallstrom O, et al. High frequency of coeliac disease in adult patients with type-I diabetes. Scand J Gastroenterol. 1989;24(1):81-84. Not about consequences of testing. [pmid: 2784589].
Collin P, Vilska S, Heinonen P K, et al. Infertility and coeliac disease. Gut. 1996;39(3):382-384. Not about consequences of testing. [pmid: 8949641]. [pmcid: 1383343].
Collin P. New diagnostic findings in coeliac disease. Ann Med. 1999;31(6):399-405. Not about consequences of testing. [pmid: 10680854].
Collin P. Serologic screening for coeliac disease--time for tissue transglutaminase test?. Ital J Gastroenterol Hepatol. 1998;30(5):498-499. Not about consequences of testing. [pmid: 9836105].
Collin Pekka, Kaukinen Katri, Valimaki Matti, et al. Endocrinological disorders and celiac disease. Endocr Rev. 2002;23(4):464-483. Not about consequences of testing. [pmid: 12202461].
Collin Pekka, Reunala Timo. Recognition and management of the cutaneous manifestations of celiac disease: a guide for dermatologists. Am J Clin Dermatol. 2003;4(1):13-20. Not about consequences of testing. [pmid: 12477369].
Collin Pekka, Syrjanen Jaana, Partanen Jukka, et al. Celiac disease and HLA DQ in patients with IgA nephropathy. Am J Gastroenterol. 2002;97(10):2572-2576. Not about consequences of testing. [pmid: 12385441].
Cook H B, Burt M J, Collett J A, et al. Adult coeliac disease: prevalence and clinical significance. Eur J Gastroenterol Hepatol. 2000;15(9):1032-1036. Not about consequences of testing.
Cooke W T, Asquith P. Coeliac disease. Introduction and definition. Clin Gastroenterol. 1974;3(1):3-10. Not about consequences of testing. [pmid: 4599070].
Coombs R R, McLaughlan P. Allergenicity of food proteins and its possible modification. Ann Allergy. 1984;53(6 Pt 2):592-596. Not about consequences of testing. [pmid: 6391288].
Coplan James. “The infant or young child with developmental delay”: Erratum. N Engl J Med. 1994;331(1):56. Not about consequences of testing.
Corazza G R, Andreani M L, Biagi F, et al. The smaller size of the ‘coeliac iceberg’ in adults. Scand J Gastroenterol. 1997;32(9):917-919. Not about consequences of testing. [pmid: 9299671].
Corazza G R, Andreani M L, Venturo N, et al. Celiac disease and alopecia areata: Report of a new association. Gastroenterology. 1995;109(4):1333-1337. Not about consequences of testing. [pmid: 7557104].
Corazza G R, Brusco G, Andreani M L, et al. Previous misdiagnosis and diagnostic delay in adult celiac sprue. J Clin Gastroenterol. 1996;22(4):324-325. Not about consequences of testing. [pmid: 8771434].
Corazza G R, Caletti G C, Lazzari R, et al. Scalloped duodenal folds in childhood celiac disease. Gastrointest Endosc. 1993;39(4):543-545. Not about consequences of testing. [pmid: 8365604].
Corazza G R, Di Sario A, Sacco G, et al. Subclinical coeliac disease: an anthropometric assessment. J Intern Med. 1994;236(2):183-187. Not about consequences of testing. [pmid: 8046318].
Corazza G R, Falasca A, Strocchi A, et al. Decreased plasma postheparin diamine oxidase levels in celiac disease. Dig Dis Sci. 1988;33(8):956-961. Not about consequences of testing. [pmid: 3134178].
Corazza G R, Gasbarrini G. Coeliac disease in adults. Bailliere's Clinical Gastroenterology. 1995;9(2):329-350. Not about consequences of testing. [pmid: 7549030].
Corazza G R, Ginaldi L, Falasca A, et al. Diamine oxidase plasma activities after treatment with heparin and jejunal morphometry in untreated coeliac disease. Am J Clin Pathol. 1989;42(11):1136-1139. Not about consequences of testing.
Corazza G R, Valentini R A, Andreani M L, et al. Subclinical coeliac disease is a frequent cause of iron-deficiency anaemia. Scand J Gastroenterol. 1995;30(2):153-156. Not about consequences of testing. [pmid: 7732338].
Corazza G, Valentini R A, Frisoni M, et al. Gliadin immune reactivity is associated with overt and latent enteropathy in relatives of celiac patients. Gastroenterology. 1992;103(5):1517-1522. Not about consequences of testing. [pmid: 1426870].
Corlin R F, Nichaman M Z, Grier O T. The use of plasma and erythrocyte phospholipid linoleate levels as a screening test for malabsorption. Am J Dig Dis. 1970;15(10):953-957. Not about consequences of testing. [pmid: 5501357].
Cornell H J, Maxwell R J. Amino acid composition of gliadin fractions which may be toxic to individuals with coeliac disease. Clin Chim Acta. 1982;123(3):311-319. Not about consequences of testing. [pmid: 6811164].
Corrao G, Corazza G R, Andreani M L, et al. Serological screening of coeliac disease: choosing the optimal procedure according to various prevalence values. Gut. 1994;35(6):771-775. Not about consequences of testing. [pmid: 8020803]. [pmcid: 1374876].
Cox M A, Lewis K O, Cooper B T. Sucrosemia in untreated celiac disease: a potential screening test. Dig Dis Sci. 1998;43(5):1096-1101. Not about consequences of testing. [pmid: 9590427].
Crawford L V, Herrod H G. Allergy diets for infants and children. Curr Probl Pediatr. 1981;11(12):1-44. Not about consequences of testing. [pmid: 7318497].
Crenn Pascal, Vahedi Kouroche, Lavergne-Slove Anne, et al. Plasma citrulline: A marker of enterocyte mass in villous atrophy-associated small bowel disease. Gastroenterology. 2003;124(5):1210-1219. Not about consequences of testing. [pmid: 12730862].
Crone J, Rami B, Huber W D, et al. Prevalence of Celiac Disease and Follow-up of Ema in Children and Adolescents With Type 1 Diabetes Mellitus. J Pediatr Gastroenterol Nutr. 2003;37(1):67-71. Not about consequences of testing. [pmid: 12827008].
Cronin C C, Feighery A, Ferriss J B, et al. High prevalence of celiac disease among patients with insulin-dependent (type I) diabetes mellitus. Am J Gastroenterol. 1997;92(12):2210-2212. Not about consequences of testing. [pmid: 9399754].
Cronin C C, Jackson L M, Feighery C, et al. Coeliac disease and epilepsy. QJM. 1998;91(4):303-308. Not about consequences of testing. [pmid: 9666954].
Cronin C C, Shanahan F. Exploring the iceberg - The spectrum of celiac disease. Am J Gastroenterol. 2003;98(3):518-520. Not about consequences of testing. [pmid: 12650779].
Cronin C C, Shanahan F. Why is celiac disease so common in Ireland?. Perspect Biol Med. 2001;44(3):342-352. Not about consequences of testing. [pmid: 11482004].
Croyle Robert T, Sun Yi, Louie Douglas H. Psychological minimization of cholesterol test results: Moderators of appraisal in college students and community residents. Health Psychol. 1993;12(6):503-507. Not about consequences of testing. [pmid: 8293735].
Csizmadia C G, Mearin M L, Oren A, et al. Accuracy and cost-effectiveness of a new strategy to screen for celiac disease in children with Down syndrome. Eur J Pediatr. 2000;137(6):756-761. Not about consequences of testing.
Cummins A G, Thompson F M, Butler R N, et al. Improvement in intestinal permeability precedes morphometric recovery of the small intestine in coeliac disease. Clin Sci (Lond). 2001;100(4):379-386. Not about consequences of testing. [pmid: 11256975].
Cuoco L, Cammarota G, Tursi A, et al. Disappearance of gastric mucosa-associated lymphoid tissue in coeliac patients after gluten withdrawal. Scand J Gastroenterol. 1998;33(4):401-405. Not about consequences of testing. [pmid: 9605262].
Cuoco L, Certo M, Jorizzo R A, et al. Prevalence and early diagnosis of coeliac disease in autoimmune thyroid disorders. Ital J Gastroenterol Hepatol. 1999;31(4):283-287. Not about consequences of testing. [pmid: 10425571].
Cuomo A, Romano M, Rocco A, et al. Reflux oesophagitis in adult coeliac disease: beneficial effect of a gluten free diet. Gut. 2003;52(4):514-517. Not about consequences of testing. [pmid: 12631661]. [pmcid: 1773586].
Dahele A, Ghosh S. Vitamin B12 deficiency in untreated celiac disease. Am J Gastroenterol. 2001;96(3):745-750. Not about consequences of testing. [pmid: 11280545].
Dahlqvist A, Lindberg T, Meeuwisse G, et al. Intestinal dipeptidases and disaccharidases in children with malabsorption. Acta Paediatr Scand. 1970;59(6):621-630. Not about consequences of testing. [pmid: 5478216].
Dahlqvist G. Celiac disease and insulin-dependent diabetes mellitus no proof for a causal association. Acta Paediatr. 1995;84(12):1337-1338. Not about consequences of testing. [pmid: 8645946].
Damoiseaux J G M C, Tervaert J W C. Celiac disease: the role of (auto)antibody detection in diagnosis and follow-up. Neth J Med. 2002;60(7):303-304. Not about consequences of testing. [pmid: 12430584].
Danielsson L, Stenhammar L, Astrom E. Is gluten challenge necessary for the diagnosis of coeliac disease in young children?. Scand J Gastroenterol. 1990;25(9):957-960. Not about consequences of testing. [pmid: 2218400].
David T J, Ajdukiewicz A B, Read A E. Fingerprint changes in coeliac disease. Br Med J. 1970;4(735):594-596. Not about consequences of testing. [pmid: 5488703]. [pmcid: 1820184].
Davidson A G, Hassall E G. Screening for celiac disease. Cmaj - Canadian Medical Association Journal = Journal De L'association Medicale Canadienne. 1997;157(5):547-548. Not about consequences of testing.
Davison S. Coeliac disease and liver dysfunction. Arch Dis Child. 2002;87(4):293-296. Not about consequences of testing. [pmid: 12243999].
Day A S, Abbott G D. Simultaneous presentation of coeliac disease and ulcerative colitis in a child. J Paediatr Child Health. 1999;35(2):204-206. Not about consequences of testing. [pmid: 10365362].
Day A S, Cook H B, Whitehead M, et al. Anti-endomysial and anti-gliadin antibodies in screening for coeliac disease in children at greater risk of developing coeliac disease. N Z Med J. 2000;113(1119):412-413. Not about consequences of testing. [pmid: 11127356].
de la, Concha E G, Fernandez-Arquero M, et al. Celiac disease and TNF promoter polymorphisms. Hum Immunol. 2000;61(5):513-517. Not about consequences of testing. [pmid: 10773355].
de Lecea A, Ribes-Koninckx C, Polanco I, et al. Serological screening (antigliadin and antiendomysium antibodies) for non-overt coeliac disease in children of short stature. Acta Paediatr. 1996;412(Suppl):54-55. Not about consequences of testing.
De Vitis I, Ghirlanda G, Gasbarrini G. Prevalence of coeliac disease in type I diabetes: a multicentre study. Acta Paediatr. 1996;412(Suppl):56-57. Not about consequences of testing.
de Vizia B, Poggi V, Conenna R, et al. Iron absorption and iron deficiency in infants and children with gastrointestinal diseases. J Pediatr Gastroenterol Nutr. 1992;14(1):21-26. Not about consequences of testing. [pmid: 1573507].
Dean G, Hanniffy L, Stevens F. Schizophrenia and coeliac disease. Ir Med J. 1975;68(21):545-546. Not about consequences of testing. [pmid: 1052488].
Del Rosario M A, Fitzgerald J F, Chong S K, et al. Further studies of anti-endomysium and anti-gliadin antibodies in patients with suspected celiac disease. J Pediatr Gastroenterol Nutr. 1998;27(2):191-195. Not about consequences of testing. [pmid: 9702652].
Demir H, Yuce A, Kocak N, et al. Celiac disease in Turkish children: presentation of 104 cases. Pediatr Int. 2000;42(5):483-487. Not about consequences of testing. [pmid: 11059535].
Deutsch J C, Santhosh-Kumar C R, Kolli V R. A noninvasive stable-isotope method to simultaneously assess pancreatic exocrine function and small bowel absorption. Am J Gastroenterol. 1995;90(12):2182-2185. Not about consequences of testing. [pmid: 8540512].
Devi Rampertab S, Fleischauer A, Neugut A I, et al. Risk of duodenal adenoma in celiac disease. Scand J Gastroenterol. 2003;38(8):831-833. Not about consequences of testing. [pmid: 12940435].
Devine P L, Birrell G W, Golder J P, et al. Screening and monitoring coeliac disease: multicentre trial of a new serum antibody test kit. Dis Markers. 1994;12(1):71-80. Not about consequences of testing. [pmid: 7842632].
Dezi R, Niveloni S, Sugai E, et al. Gluten sensitivity in the rectal mucosa of first-degree relatives of celiac disease patients. Am J Gastroenterol. 1997;92(8):1326-1330. Not about consequences of testing. [pmid: 9260799].
Dhar A, Goenka M K. Endomysial antibody and celiac disease. Indian Journal of Gastroenterology - Official Journal of the Indian Society of Gastroenterology. 1993;12(4):157-158. Not about consequences of testing. [pmid: 8270300].
Di Cagno, Raffaella De, Angelis Maria, et al. Proteolysis by sourdough lactic acid bacteria: effects on wheat flour protein fractions and gliadin peptides involved in human cereal intolerance. Appl Environ Microbiol. 2002;68(2):623-633. Not about consequences of testing. [pmid: 11823200]. [pmcid: 126681].
Di Leo M, Weisz G, Ansaldi Balocco N. Serum and salivary antiendomysium antibodies in the screening of coeliac disease. Panminerva Med. 1999;41(1):68-71. Not about consequences of testing. [pmid: 10230262].
Dias J, Unsworth D J, Walker-Smith J A. Antigliadin and antireticulin antibodies in screening for coeliac disease. Lancet. 1987;2(8551):157-158. Not about consequences of testing. [pmid: 2885617].
Dickey W, Hughes D F, McMillan S A. Reliance on serum endomysial antibody testing underestimates the true prevalence of coeliac disease by one fifth. Scand J Gastroenterol. 2000;35(2):181-183. Not about consequences of testing. [pmid: 10720117].
Dickey W, Hughes D. Disappointing sensitivity of endoscopic markers for villous atrophy in a high-risk population: implications for celiac disease diagnosis during routine endoscopy. Am J Gastroenterol. 2001;96(7):2126-2128. Not about consequences of testing. [pmid: 11467643].
Dickey W, Hughes D. Prevalence of celiac disease and its endoscopic markers among patients having routine upper gastrointestinal endoscopy. Am J Gastroenterol. 1999;94(8):2182-2186. Not about consequences of testing. [pmid: 10445547].
Dickey W, McConnell J B. How many hospital visits does it take before celiac sprue is diagnosed?. J Clin Gastroenterol. 1996;23(1):21-23. Not about consequences of testing. [pmid: 8835909].
Dickey W, McMillan S A, Bharucha C, et al. Antigliadin antibodies in blood donors in Northern Ireland. Eur J Gastroenterol Hepatol. 1992;4(9):739-741. Not about consequences of testing.
Dickey W, McMillan S A, Callender M E. High prevalence of celiac sprue among patients with primary biliary cirrhosis. J Clin Gastroenterol. 1997;25(1):328-329. Not about consequences of testing. [pmid: 9412913].
Dickey W, McMillan S A, Hughes D F. Identification of coeliac disease in primary care. Scand J Gastroenterol. 1998;33(5):491-493. Not about consequences of testing. [pmid: 9648987].
Dickey W, McMillan S A, Hughes D F. Sensitivity of serum tissue transglutaminase antibodies for endomysial antibody positive and negative coeliac disease. Scand J Gastroenterol. 2001;36(5):511-514. Not about consequences of testing. [pmid: 11346205].
Dickey W, McMillan S A, McCrum E E, et al. Association between serum levels of total IgA and IgA class endomysial and antigliadin antibodies: implications for coeliac disease screening. Eur J Gastroenterol Hepatol. 1997;9(6):559-562. Not about consequences of testing. [pmid: 9222726].
Dickey W, Stewart F, Nelson J, et al. Screening for coeliac disease as a possible maternal risk factor for neural tube defect. Clin Genet. 1996;49(2):107-108. Not about consequences of testing. [pmid: 8740924].
Dieterich W, Ehnis T, Bauer M, et al. Identification of tissue transglutaminase as the autoantigen of celiac disease. Nat Med. 1997;3(7):797-801. Not about consequences of testing. [pmid: 9212111].
Dieterich W, Laag E, Bruckner-Tuderman L, et al. Antibodies to tissue transglutaminase as serologic markers in patients with dermatitis herpetiformis. J Invest Dermatol. 1999;113(1):133-136. Not about consequences of testing. [pmid: 10417632].
Dieterich W, Laag E, Schopper H, et al. Autoantibodies to tissue transglutaminase as predictors of celiac disease. Gastroenterology. 1998;115(6):1317-1321. Not about consequences of testing. [pmid: 9834256].
Digilio M C, Giannotti A, Castro M, et al. Screening for Celiac Disease in Patients With Deletion 22q11.2 (Digeorge/Velo-Cardio-Facial Syndrome). Am J Med Genet. 2003;121A(3):286-288. Not about consequences of testing. [pmid: 12923874].
Dinari G, Rosenbach Y, Zahavi I, et al. Random fecal alpha 1-antitrypsin excretion in children with intestinal disorders. Am J Dis Child. 1984;138(10):971-973. Not about consequences of testing. [pmid: 6332527].
Dinari G, Zahavi I, Marcus H, et al. Placental ferritin in coeliac disease: relation to clinical stage, origin, and possible role in the pathogenesis of malignancy. Gut. 1991;32(9):999-1003. Not about consequences of testing. [pmid: 1916505]. [pmcid: 1379037].
Dissanayake A S, Truelove S C, Whitehead R. Jejunal mucosal recovery in coeliac disease in relation to the degree of adherence to a gluten-free diet. Q J Med. 1974;43(170):161-185. Not about consequences of testing. [pmid: 4604652].
Drossman D A. Irritable bowel syndrome: how far do you go in the workup?. Gastroenterology. 2001;121(6):1512-1515. Not about consequences of testing. [pmid: 11729133].
Duncan A, Park R P, Lee F D, et al. A retrospective assessment of the clinical value of jejunal disaccharidase analysis. Scand J Gastroenterol. 1994;29(12):1111-1116. Not about consequences of testing. [pmid: 7886399].
Eade O E, Lloyd R S, Lang C, et al. IgA and IgG reticulin antibodies in coeliac and non-coeliac patients. Gut. 1977;18(12):991-993. Not about consequences of testing. [pmid: 342356]. [pmcid: 1411833].
Eigenmann P A, Calza A-M. Diagnosis of IgE-mediated food allergy among Swiss children with atopic dermatitis. Pediatr Allergy Immunol. 2000;11(2):95-100. Not about consequences of testing. [pmid: 10893011].
Eigenmann P A, Sicherer S H, Borkowski T A, et al. Prevalence of IgE-mediated food allergy among children with atopic dermatitis. Pediatrics. 1998;101(3):E8. Not about consequences of testing. [pmid: 9481027].
Einarsson K, Bjorkhem I, Eklof R, et al. 14C-triolein breath test as a rapid and convenient screening test for fat malabsorption. Scand J Gastroenterol. 1983;18(1):9-12. Not about consequences of testing. [pmid: 6675178].
Elewaut A, Dacremont G, Robberecht E, et al. IgA isotyping of antigliadin antibodies. A possible clue for a less invasive diagnosis of coeliac disease. Clin Chim Acta. 1989;183(3):285-294. Not about consequences of testing. [pmid: 2805354].
Ensari A, Marsh M N, Morgan S, et al. Diagnosing coeliac disease by rectal gluten challenge: a prospective study based on immunopathology, computerized image analysis and logistic regression analysis. Clin Sci (Lond). 2001;101(2):199-207. Not about consequences of testing. [pmid: 11473497].
Enzenauer R J, Root S. Arthropathy and celiac disease. J Clin Rheumatol. 1998;4(4):205-208. Not about consequences of testing. [pmid: 19078293].
Erfurt John C, Foote Andrea, Heirich Max A. Worksite wellness programs: Incremental comparison of screening and referral alone, health education, follow-up counseling, and plant organization. Am J Health Promot. 1991;5(6):438-448. Not about consequences of testing. [pmid: 10148672].
Exner G U, Sacher M, Shmerling D H, et al. Growth retardation and bone mineral status in children with coeliac disease recognized after the age of 3 years. Helv Paediatr Acta. 1978;33(6):497-507. Not about consequences of testing. [pmid: 216653].
Fabiani E, Catassi C. The serum IgA class anti-tissue transglutaminase antibodies in the diagnosis and follow up of coeliac disease. Results of an international multi-centre study. International Working Group on Eu-tTG. Eur J Gastroenterol Hepatol. 2001;13(6):659-665. Not about consequences of testing. [pmid: 11434591].
Farre C, Esteve M, Curcoy A, et al. Hypertransaminasemia in pediatric celiac disease patients and its prevalence as a diagnostic clue. Am J Gastroenterol. 2002;97(12):3176-3181. Not about consequences of testing. [pmid: 12492207].
Farre C, Humbert P, Vilar P, et al. Serological markers and HLA-DQ2 haplotype among first-degree relatives of celiac patients. Catalonian Coeliac Disease Study Group. Dig Dis Sci. 1999;44(11):2344-2349. Not about consequences of testing. [pmid: 10573385].
Farrell R J, Kelly C P. Diagnosis of celiac sprue. Am J Gastroenterol. 2001;96(12):3237-3246. Not about consequences of testing. [pmid: 11774931].
Farrell Richard J, Kelly Ciaran P. Celiac sprue. N Engl J Med. 2002;346(3):180-188. Not about consequences of testing. [pmid: 12168643].
Fasano A, Catassi C. Current approaches to diagnosis and treatment of celiac disease: an evolving spectrum. Gastroenterology. 2001;120(3):636-651. Not about consequences of testing. [pmid: 11179241].
Fasano A. European and North American populations should be screened for coeliac disease. Gut. 2003;52(2):168-169. Not about consequences of testing. [pmid: 12524403]. [pmcid: 1774954].
Fasano A. Where have all the American celiacs gone?. Acta Paediatr. 1996;412(Suppl):20-24. Not about consequences of testing.
Fasano Alessio, Berti Irene, Gerarduzzi Tania, et al. Prevalence of celiac disease in at-risk and not-at-risk groups in the United States: a large multicenter study. Arch Intern Med. 2003;163(3):286-292. Not about consequences of testing. [pmid: 12578508].
Fasano Alessio. Celiac disease--how to handle a clinical chameleon. N Engl J Med. 2003;348(25):2568-2570. Not about consequences of testing. [pmid: 12815143].
Feighery C, Weir D G, Whelan A, et al. Diagnosis of gluten-sensitive enteropathy: is exclusive reliance on histology appropriate?. Eur J Gastroenterol Hepatol. 1998;10(11):919-925. Not about consequences of testing. [pmid: 9872613].
Feighery C. Coeliac disease. Br Med J. 1999;319(7204):236-239. Not about consequences of testing. [pmid: 10417090]. [pmcid: 1116331].
Ferfoglia G, Pulitano R, Sategna-Guidetti C. Do dietary antibodies still play a role in the diagnosis and follow-up of coeliac disease? A comparison among different serological tests. Panminerva Med. 1995;37(2):55-59. Not about consequences of testing. [pmid: 8637769].
Ferguson A, Denton-Miller P, Lai C L. Coeliac disease--objectives of life-long follow-up. Health Bull (Edinb). 1977;35(2):78-80. Not about consequences of testing. [pmid: 404272].
Fernandez-Calle P, Codoceo R, Polanco I, et al. Is an intestinal permeability test a valid marker for slight dietary transgressions in adolescents with coeliac disease?. Gut. 1993;34(6):774-777. Not about consequences of testing. [pmid: 8314509]. [pmcid: 1374260].
Fernhall Bo, Tymeson Garth, Millar Lynn, et al. Cardiovascular fitness testing and fitness levels of adolescents and adults with mental retardation including Down syndrome. Education & Training in Mental Retardation. 1989;24(2):133-138. Not about consequences of testing.
Ferreira M, Davies S L, Butler M, et al. Endomysial antibody: is it the best screening test for coeliac disease?. Gut. 1992;33(12):1633-1637. Not about consequences of testing. [pmid: 1487164]. [pmcid: 1379574].
Fiasse R. Screening for gastrointestinal diseases - Therapeutic impact. Acta Gastro-Enterol Belg. 1995;58(56):343-347. Unable to obtain article.
Fielding Jonathan E. Frequency of health risk assessment activities at U.S. worksites. Am J Prev Med. 1989;5(2):73-81. Not about consequences of testing. [pmid: 2730795].
Fine K D, Lee E L, Meyer R L. Colonic histopathology in untreated celiac sprue or refractory sprue: is it lymphocytic colitis or colonic lymphocytosis?. Hum Pathol. 1998;29(12):1433-1440. Not about consequences of testing. [pmid: 9865829].
Fine K D, Ogunji F, George J, et al. Utility of a rapid fecal latex agglutination test detecting the neutrophil protein, lactoferrin, for diagnosing inflammatory causes of chronic diarrhea. Am J Gastroenterol. 1998;93(8):1300-1305. Not about consequences of testing. [pmid: 9707055].
Fine K D, Ogunji F, Saloum Y, et al. Celiac sprue: another autoimmune syndrome associated with hepatitis C. Am J Gastroenterol. 2001;96(1):138-145. Not about consequences of testing. [pmid: 11197243].
Fink Raymond, Shapiro Sam. Significance of increased efforts to gain participation in screening for breast cancer. Am J Prev Med. 1990;6(1):34-41. Not about consequences of testing. [pmid: 2187496].
First Lewis R, Palfrey Judith S. The infant or young child with developmental delay. N Engl J Med. 1994;330(7):478-483. Not about consequences of testing. [pmid: 7507219].
Fisher S E, Markowitz J, Lifshitz F. Food intolerance in childhood. Compr Ther. 1984;10(5):5-11. Not about consequences of testing. [pmid: 6547381].
Fitzpatrick K P, Sherman P M, Ipp M, et al. Screening for celiac disease in children with recurrent abdominal pain. J Pediatr Gastroenterol Nutr. 2001;33(3):250-252. Not about consequences of testing. [pmid: 11593117].
Flanders G, Graves P, Rewers M. Prevention of type 1 diabetes from laboratory to public health. Autoimmunity. 1999;29(3):235-246. Not about consequences of testing. [pmid: 10433102].
Floreani A, Betterle C, Baragiotta A, et al. Prevalence of coeliac disease in primary biliary cirrhosis and of antimitochondrial antibodies in adult coeliac disease patients in Italy. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(4):258-261. Not about consequences of testing. [pmid: 12038809].
Foldes-Papp Zeno, Demel Ulrike, Berry Desiree, et al. Tissue transglutaminase antibody determination in celiac disease. Analysis of diagnostic specificity of anti-human IgA-type assays. J Immunoassay Immunochem. 2002;23(2):211-227. Not about consequences of testing. [pmid: 12033644].
Foster P N, Will E J, Kelleher J, et al. Oxalate-loading tests to screen for steatorrhoea: an appraisal. Clin Chim Acta. 1984;144(23):155-161. Not about consequences of testing. [pmid: 6529853].
Fotherby K J, Wraight E P, Neale G. 51Cr-EDTA/14C-mannitol intestinal permeability test. Clinical use in screening for coeliac disease. Scand J Gastroenterol. 1988;23(2):171-177. Not about consequences of testing. [pmid: 3129775].
Fotoulaki M, Nousia-Arvanitakis S, Augoustidou-Savvopoulou P, et al. Clinical application of immunological markers as monitoring tests in celiac disease. Dig Dis Sci. 1999;44(10):2133-2138. Not about consequences of testing. [pmid: 10548368].
Fox Sarah A, Klos Dennis S, Tsou Carole V, et al. Breast cancer screening recommendations: Current status of women's knowledge. Fam Community Health. 1987;10(3):39-50. Not about consequences of testing.
Fox Sarah A, Stein Judith A. The effect of physician^patient communication on mammography utilization by different ethnic groups. Med Care. 1991;29(11):1065-1082. Not about consequences of testing. [pmid: 1943268].
Francis James, Carty John E, Scott Brian B. The prevalence of coeliac disease in rheumatoid arthritis. Eur J Gastroenterol Hepatol. 2002;14(12):1355-1356. Not about consequences of testing. [pmid: 12468957].
Francis Rupert A, Ernst Frederick A, Nevels Harold, et al. The relationship of blood pressure to a brief measure of anger during routine health screening. J Natl Med Assoc. 1991;83(7):601-604. Not about consequences of testing. [pmid: 1920517].
Franklin R H. Post-vagotomy diarrhoea?. Br Med J. 1970;1(693):412. Not about consequences of testing. [pmid: 5434662]. [pmcid: 1699229].
Franks Peter, Clancy Carolyn M. Physician gender bias in clinical decisionmaking: Screening for cancer in primary care. Med Care. 1993;31(3):213-218. Not about consequences of testing. [pmid: 8450679].
Fraser-Reynolds K A, Butzner J D, Stephure D K, et al. Use of immunoglobulin A-antiendomysial antibody to screen for celiac disease in North American children with type 1 diabetes. Diabetes Care. 1998;21(11):1985-1989. Not about consequences of testing. [pmid: 9802755].
Fredriksson Hans. Screening of mental disturbances in occupational health services in Finland. Psychiatria Fennica 1987;18133–143. Not about consequences of testing
Freeman H J. Failure of added dietary gluten to induce small intestinal histopathological changes in patients with watery diarrhea and lymphocytic colitis. Can J Gastroenterol. 1996;10(7):436-439. Not about consequences of testing. [pmid: 9113886].
Freeman H J. Small intestinal mucosal biopsy for investigation of diarrhea and malabsorption in adults. Gastrointest Endosc Clin N Am 2000;10(4):739–53, Vii. Not about consequences of testing
Freeman H J. Solid-phase ELISA for tissue transglutaminase, an endomysial target for possible serological diagnosis of celiac disease. Can J Gastroenterol. 1998;12(5):323-324. Not about consequences of testing. [pmid: 10206732].
Freeman H J. Survey of gastroenterologists on the diagnosis and treatment of adult patients with celiac disease in British Columbia. Can J Gastroenterol. 1998;12(2):149-152. Not about consequences of testing. [pmid: 10206732].
Freeman Hugh, Lemoyne Michel, Pare Pierre. Coeliac disease. Baillieres Best Pract Res Clin Gastroenterol. 2002;16(1):37-49. Not about consequences of testing.
Freemark M, Levitsky L L. Screening for celiac disease in children with type 1 diabetes: Two views of the controversy. Diabetes Care. 2003;26(6):1932-1939. Not about consequences of testing. [pmid: 12766138].
Freier S. Paediatric gastrointestinal allergy. Clin Allergy. 1973;3(Suppl):597-618. Not about consequences of testing. [pmid: 4620910].
Fried Terri R, Rosenberg Roberta R, Lipsitz Lewis A. Older community-dwelling adults' attitudes toward and practices of health promotion and advance planning activities. J Am Geriatr Soc. 1995;43(6):645-649. Not about consequences of testing. [pmid: 7775723].
Friedman Lawrence S, Johnson Brenda, Brett Allan S. Evaluation of substance-abusing adolescents by primary care physicians. J Adolesc Health Care. 1990;11(3):227-230. Not about consequences of testing. [pmid: 2358391].
Friedman Lois C, Woodruff Amy, Lane Montague, et al. Breast cancer screening behaviors and intentions among asymptomatic women 50 years of age and older. Am J Prev Med. 1995;11(4):218-223. Not about consequences of testing. [pmid: 7495597].
Friis S U, Gudmand-Hoyer E. Screening for coeliac disease in adults by simultaneous determination of IgA and IgG gliadin antibodies. Scand J Gastroenterol. 1986;21(9):1058-1062. Not about consequences of testing. [pmid: 3810005].
Frisoni G B, Carabellese N, Longhi M, et al. Is celiac disease associated with Alzheimer's disease?. Acta Neurol Scand. 1997;95(3):147-151. Not about consequences of testing. [pmid: 9088382].
Fromm H, Hofmann A F. Breath test for altered bile-acid metabolism. Lancet. 1971;2(7725):621-625. Not about consequences of testing. [pmid: 4105944].
Frustaci Andrea, Cuoco Lucio, Chimenti Cristina, et al. Celiac disease associated with autoimmune myocarditis. Circulation. 2002;105(22):2611-2618. Not about consequences of testing. [pmid: 12045166].
Fry L. Dermatitis herpetiformis. Bailliere's Clinical Gastroenterology. 1995;9(2):371-393. Not about consequences of testing. [pmid: 7549032].
Fry L. The gut and dermatitis herpetiformis. Br Med J. 1971;4(780):172. Not about consequences of testing. [pmid: 5113033].
Fung V S, Duggins A, Morris J G, et al. Progressive myoclonic ataxia associated with celiac disease presenting as unilateral cortical tremor and dystonia. Mov Disord. 2000;15(4):732-734. Not about consequences of testing. [pmid: 10928587].
Gale J, Simmonds P D, Mead G M, et al. Enteropathy-type intestinal T-cell lymphoma: clinical features and treatment of 31 patients in a single center. Journal of Clinical Oncology - Official Journal of the American Society of Clinical Oncology. 2000;18(4):795-803. Not about consequences of testing. [pmid: 10673521].
Gandolfi L, Catassi C, Garcia S, et al. Antiendomysial antibody test reliability in children with frequent diarrhea and malnutrition: is it celiac disease?. J Pediatr Gastroenterol Nutr. 2001;33(4):483-487. Not about consequences of testing. [pmid: 11698768].
Gandolfi L, Pratesi R, Cordoba J C, et al. Prevalence of celiac disease among blood donors in Brazil. Am J Gastroenterol. 2000;95(3):689-692. Not about consequences of testing. [pmid: 10710058].
Gardiner A, Porteous N, Walker-Smith J A. The effect of coeliac disease on the mother-child relationship. Aust Paediatr J. 1972;8(1):39-43. Unable to obtain article. [pmid: 5045509].
Garioch J J, Lewis H M, Sargent S A, et al. 25 years' experience of a gluten-free diet in the treatment of dermatitis herpetiformis. Br J Dermatol. 1994;131(4):541-545. Not about consequences of testing. [pmid: 7947207].
Garn S M, Poznanski A K, Nagy J M. Bone measurement in the differential diagnosis of osteopenia and osteoporosis. Radiology. 1971;100(3):509-518. Not about consequences of testing. [pmid: 4254881].
Garrote J A, Sorell L, Alfonso P, et al. A novel visual immunoassay for coeliac disease screening. Eur J Clin Invest. 1999;29(8):697-699. Not about consequences of testing. [pmid: 10457154].
Gasbarrini Antonio, Ojetti Veronica, Cuoco Lucio, et al. Lack of endoscopic visualization of intestinal villi with the “immersion technique” in overt atrophic celiac disease. Gastrointest Endosc. 2003;57(3):348-351. Not about consequences of testing. [pmid: 12612514].
Gaston Marilyn, Hughes Moody, Lanardo E. Improving utilization of breast and cervical cancer screening in your office practice. J Natl Med Assoc. 1995;87(9):700-704. Not about consequences of testing. [pmid: 9583967].
Gath D H, Hallam N, Mynors-Wallis L, et al. Emotional reactions in women attending a UK colposcopy clinic. J Epidemiol Community Health. 1995;49(1):79-83. Not about consequences of testing. [pmid: 7707011].
Gawkrodger D J, Vestey J P, O'Mahony S, et al. Dermatitis herpetiformis and established coeliac disease. Br J Dermatol. 1993;129(6):694-695. Not about consequences of testing. [pmid: 8286252].
George E K, Hertzberger-ten Cate R, Suijlekom-Smit L W, et al. Juvenile chronic arthritis and coeliac disease in The Netherlands. Clin Exp Rheumatol. 1996;14(5):571-575. Not about consequences of testing. [pmid: 8913663].
George E K, Mearin M L, Bouquet J, et al. High frequency of celiac disease in Down syndrome. Eur J Pediatr. 1996;128(4):555-557. Not about consequences of testing.
George E K, Mearin M L, Bouquet J, et al. Screening for coeliac disease in Dutch children with associated diseases. Acta Paediatr. 1996;412(Suppl):52-53. Not about consequences of testing.
George Sharon A. Barriers to breast cancer screening: An integrative review. Health Care Women Int. 2000;21(1):53-65. Not about consequences of testing. [pmid: 11022449].
Gerrard J W, Lubos M C. The malabsorption syndromes. Pediatr Clin North Am. 1967;14(1):73-91. Not about consequences of testing. [pmid: 5334379].
Gersch Irvine, Kelly Catherine, Cohen Sara, et al. The Chingford Hall School Screening Project: Can we have some more educational psychologist time please?. Educational Psychology in Practice. 2001;17(2):135-156. Not about consequences of testing.
Ghosh S K, Littlewood J M, Goddard D, et al. Stool microscopy in screening for steatorrhoea. Am J Clin Pathol. 1977;30(8):749-753. Not about consequences of testing.
Giannotti A, Tiberio G, Castro M, et al. Coeliac disease in Williams syndrome. J Med Genet. 2001;38(11):767-768. Not about consequences of testing. [pmid: 11694549].
Gilchrist C N, Espinar E A, Cook H B. Familial short stature and coeliac disease: A family case report. N Z Med J. 1983;96(736):563-565. Not about consequences of testing. [pmid: 6575296].
Gilett P M, Gilett H R, Israel D M, et al. Increased prevalence of celiac disease in girls with Turner syndrome detected using antibodies to endomysium and tissue transglutaminase. Can J Gastroenterol. 2000;14(11):915-918. Not about consequences of testing. [pmid: 11125180].
Gillberg R, Ahren C. Coeliac disease diagnosed by means of duodenoscopy and endoscopic duodenal biopsy. Scand J Gastroenterol. 1977;12(8):911-916. Not about consequences of testing. [pmid: 605350].
Gillett H R, Cauch-Dudek K, Jenny E, et al. Prevalence of IgA antibodies to endomysium and tissue transglutaminase in primary biliary cirrhosis. Can J Gastroenterol. 2000;14(8):672-675. Not about consequences of testing. [pmid: 11185531].
Gillett H R, Freeman H J. Comparison of IgA endomysium antibody and IgA tissue transglutaminase antibody in celiac disease. Can J Gastroenterol. 2000;14(8):668-671. Not about consequences of testing. [pmid: 11185531].
Gillett H R, Freeman H J. Serological testing in screening for adult celiac disease. Can J Gastroenterol. 1999;13(3):265-269. Not about consequences of testing. [pmid: 10331939].
Gillett P M, Gillett H R, Israel D M, et al. High prevalence of celiac disease in patients with type 1 diabetes detected by antibodies to endomysium and tissue transglutaminase. Can J Gastroenterol. 2001;15(5):297-301. Not about consequences of testing. [pmid: 11381296].
Gillett P M, Gillett H R, Israel D M, et al. Increased prevalence of celiac disease in girls with Turner syndrome detected using antibodies to endomysium and tissue transglutaminase. Can J Gastroenterol. 2000;14(11):915-918. Not about consequences of testing. [pmid: 11125180].
Gillett P M, Israel D M. Tissue transglutaminase: does the key fit the celiac lock?. J Pediatr Gastroenterol Nutr. 2000;30(2):222-223. Not about consequences of testing. [pmid: 10697147].
Gomez J C, Selvaggio G S, Viola M, et al. Prevalence of celiac disease in Argentina: screening of an adult population in the La Plata area. Am J Gastroenterol. 2001;96(9):2700-2704. Not about consequences of testing. [pmid: 11569698].
Gomez Juan C, Selvaggio Gisella, Pizarro Bibiana, et al. Value of a screening algorithm for celiac disease using tissue transglutaminase antibodies as first level in a population-based study. Am J Gastroenterol. 2002;97(11):2785-2790. Not about consequences of testing. [pmid: 12425549].
Gonczi J, Skerritt J H, Mitchell J D. A reliable screening test for coeliac disease: enzyme-linked immunosorbent assay to detect anti-gliadin antibodies in serum. Aust N Z J Med. 1991;21(5):723-731. Not about consequences of testing. [pmid: 1759921].
Gonczi J, Skerritt J H, Mitchell J D. Differentiation of coeliac disease and other malabsorption diseases using specific serum antigliadin IgG subclass profiles and IgA1 levels. Int Arch Allergy Immunol. 1992;98(4):377-385. Not about consequences of testing. [pmid: 1422265].
Gonzalez D, Sugai E, Gomez J C, et al. Is it necessary to screen for celiac disease in postmenopausal osteoporotic women?. Calcif Tissue Int. 2002;71(2):141-144. Not about consequences of testing. [pmid: 12200648].
Gordon N. Cerebellar ataxia and gluten sensitivity: a rare but possible cause of ataxia, even in childhood. Dev Med Child Neurol. 2000;42(4):283-286. Not about consequences of testing. [pmid: 10755462].
Gould S R, Chinn G L, Nobbs B T, et al. Evaluation of a tubeless pancreatic function test in patients with steatorrhoea in a district general hospital. J R Soc Med. 1988;81(5):270-273. Not about consequences of testing. [pmid: 3290481]. [pmcid: 1291585].
Gracey M. Another screening test for coeliac disease?. Aust Paediatr J. 1974;10(6):367-370. Not about consequences of testing. [pmid: 4462534].
Granot E, Korman S M, Sallon S, et al. “Early” vs. “late” diagnosis of celiac disease in two ethnic groups living in the same geographic area. Isr J Med Sci. 1994;30(4):271-275. Not about consequences of testing. [pmid: 8175328].
Greco L, Babron M C, Corazza G R, et al. Existence of a genetic risk factor on chromosome 5q in Italian coeliac disease families. Ann Hum Genet. 2001;65(Pt 1):35-41. Not about consequences of testing. [pmid: 11415521].
Greco L, Corazza G, Babron M C, et al. Genome search in celiac disease. Am J Hum Genet. 1998;62(3):669-675. Not about consequences of testing. [pmid: 9497251]. [pmcid: 1376948].
Greco L, D'Adamo G, Truscelli A, et al. Intestinal permeability after single dose gluten challenge in coeliac disease. Arch Dis Child. 1991;66(7):870-872. Not about consequences of testing. [pmid: 1863103].
Greco L, Percopo S, Clot F, et al. Lack of correlation between genotype and phenotype in celiac disease. J Pediatr Gastroenterol Nutr. 1998;26(3):286-290. Not about consequences of testing. [pmid: 9523863].
Greco L, Percopo S. The coeliac disease task force “Free from Gluten,” “Improved knowledge to cure coeliac disease”. Acta Paediatr. 1996;412(Suppl):25-28. Not about consequences of testing.
Greco L, Romino R, Coto I, et al. The first large population based twin study of coeliac disease. Gut. 2002;50(5):624-628. Not about consequences of testing. [pmid: 11950806]. [pmcid: 1773191].
Greco L, Troncone R, de Vizia B, et al. Discriminant analysis for the diagnosis of childhood celiac disease. J Pediatr Gastroenterol Nutr. 1987;6(4):538-542. Not about consequences of testing. [pmid: 3430260].
Greco L, Troncone R. Coeliac families. Acta Paediatr. 2002;91(1):16-17. Not about consequences of testing. [pmid: 11883812].
Green P H, Shane E, Rotterdam H, et al. Significance of unsuspected celiac disease detected at endoscopy. Gastrointest Endosc. 2000;51(1):60-65. Not about consequences of testing. [pmid: 10625798].
Green P H R, Stavropoulos S N, Panagi S G, et al. Characteristics of adult celiac disease in the USA: results of a national survey. Am J Gastroenterol. 2001;96(1):126-131. Not about consequences of testing. [pmid: 11197241].
Greenberger N J, Saegh S, Ruppert R D. Urine indican excretion in malabsorptive disorders. Gastroenterology. 1968;55(2):204-211. Not about consequences of testing. [pmid: 4385691].
Grodzinsky E, Hed J, Lieden G, et al. Presence of IgA and IgG antigliadin antibodies in healthy adults as measured by micro-ELISA. Effect of various cutoff levels on specificity and sensitivity when diagnosing coeliac disease. Int Arch Allergy Appl Immunol. 1990;92(2):119-123. Not about consequences of testing. [pmid: 2242925].
Grodzinsky E, Hed J, Skogh T. IgA antiendomysium antibodies have a high positive predictive value for celiac disease in asymptomatic patients. Allergy. 1994;49(8):593-597. Not about consequences of testing. [pmid: 7653735].
Grodzinsky E, Ivarsson A, Juto P, et al. New automated immunoassay measuring immunoglobulin A antigliadin antibodies for prediction of celiac disease in childhood. Clin Diagn Lab Immunol. 2001;8(3):564-570. Not about consequences of testing. [pmid: 11329459]. [pmcid: 96102].
Grodzinsky E, Jansson G, Skogh T, et al. Anti-endomysium and anti-gliadin antibodies as serological markers for coeliac disease in childhood: a clinical study to develop a practical routine. Acta Paediatr. 1995;84(3):294-298. Not about consequences of testing. [pmid: 7780251].
Grodzinsky E. Screening for coeliac disease in apparently healthy blood donors. Acta Paediatr. 1996;412(Suppl):36-38. Not about consequences of testing.
Grunbaum Jo A, Rodriguez Beatriz L, Labarthe Darwin R. Parental response to identification of elevated blood pressure or cholesterol following school-based screening. J Adolesc Health. 1993;14(2):99-103. Not about consequences of testing. [pmid: 8476880].
Guandalini Stefano. Celiac disease. School Nurse News. 2003;20(2):24-27. Not about consequences of testing. [pmid: 12683313].
Guinnepain M T, Eloit C, Raffard M, et al. Exercise-induced anaphylaxis: useful screening of food sensitization. Annals of Allergy, Asthma & Immunology - Official Publication of the American College of Allergy, Asthma, & Immunology. 1996;77(6):491-496. Not about consequences of testing. [pmid: 8970441].
Gupta S K, Bhu N, Singh P P, et al. Oxalate loading test for screening steatorrhoea in diabetics. Jpn J Exp Med. 1987;57(3):141-143. Not about consequences of testing. [pmid: 3682230].
Guvenc cedil, Kaymakog caron, Gurel N, et al. The prevalence of manifest and latent celiac disease in type 1 diabetes mellitus. Turk J Gastroenterol. 2002;13(2):103-107. Not about consequences of testing. [pmid: 16378286].
Habior Andrzej, Lewartowska Aleksandra, Orlowska Janina, et al. Association of coeliac disease with primary biliary cirrhosis in Poland. Eur J Gastroenterol Hepatol. 2003;15(2):159-164. Not about consequences of testing. [pmid: 12560760].
Hadjivassiliou M, Davies-Jones G A B, Sanders D S, et al. Dietary treatment of gluten ataxia. J Neurol Neurosurg Psychiatry. 2003;74(9):1221-1224. Not about consequences of testing. [pmid: 12933922].
Hadjivassiliou M, Gibson A, Davies-Jones G A, et al. Does cryptic gluten sensitivity play a part in neurological illness?. Lancet. 1996;347(8998):369-371. Not about consequences of testing. [pmid: 8598704].
Hadjivassiliou M, Grunewald R A, Chattopadhyay A K, et al. Clinical, radiological, neurophysiological, and neuropathological characteristics of gluten ataxia. Lancet. 1998;352(9140):1582-1585. Not about consequences of testing. [pmid: 9843103].
Hadjivassiliou Marios, Grunewald Richard, Sharrack Basil, et al. Gluten ataxia in perspective: epidemiology, genetic susceptibility and clinical characteristics. Brain Dev. 2003;126(Pt 3):685-691. Not about consequences of testing.
Hadziselimovic F, Emmons L R, Schaub U, et al. Occurrence of large granular lymphocytes and natural killer cells in the epithelium of the gut distinguishes two different coeliac diseases. Gut. 1992;33(6):767-772. Not about consequences of testing. [pmid: 1624157]. [pmcid: 1379333].
Hakeem V, Fifield R, al Bayaty H F, et al. Salivary IgA antigliadin antibody as a marker for coeliac disease. Arch Dis Child. 1992;67(6):724-727. Not about consequences of testing. [pmid: 1626993].
Hall W H. Proximal muscle atrophy in adult celiac disease. Am J Dig Dis. 1968;13(8):697-704. Not about consequences of testing. [pmid: 5667929].
Hallert C, Astrom J. Intellectual ability of adults after lifelong intestinal malabsorption due to coeliac disease. J Neurol Neurosurg Psychiatry. 1983;46(1):87-89. Not about consequences of testing. [pmid: 6842207].
Hallert C, Granno C, Grant C, et al. Quality of life of adult coeliac patients treated for 10 years. Scand J Gastroenterol. 1998;33(9):933-938. Not about consequences of testing. [pmid: 9759948].
Hallert C, Granno C, Hulten S, et al. Living with coeliac disease: controlled study of the burden of illness. Scand J Gastroenterol. 2002;37(1):39-42. Not about consequences of testing. [pmid: 11843033].
Hallert C, Lohiniemi S. Quality of life of celiac patients living on a gluten-free diet. Nutrition. 1999;15(10):795-797. Not about consequences of testing. [pmid: 10501298].
Hallert C, Tobiasson P, Walan A. Serum folate determinations in tracing adult coeliacs. Scand J Gastroenterol. 1981;16(2):263-267. Not about consequences of testing. [pmid: 7313538].
Hallstrom O. Comparison of IgA-class reticulin and endomysium antibodies in coeliac disease and dermatitis herpetiformis. Gut. 1989;30(9):1225-1232. Not about consequences of testing. [pmid: 2806989]. [pmcid: 1434235].
Hamilton J R, McNeill L K. Childhood celiac disease: response of treated patients to a small uniform daily dose of wheat gluten. Eur J Pediatr. 1972;81(5):885-893. Not about consequences of testing.
Hanasz-Jarzynska T, Ignys I. Infantile colic and food allergy. Int Rev Allergol Clin Immunol. 1998;4(3):111-114. Not about consequences of testing.
Hankey G L, Holmes G K. Coeliac disease in the elderly. Gut. 1994;35(1):65-67. Not about consequences of testing. [pmid: 8307452]. [pmcid: 1374634].
Hansen D, Bennedbaek F N, Hansen L K, et al. High prevalence of coeliac disease in Danish children with type I diabetes mellitus. Acta Paediatr. 2001;90(11):1238-1243. Not about consequences of testing. [pmid: 11808892].
Hanson L A. Human milk and host defence: immediate and long-term effects. Acta Paediatr Suppl. 1999;88(430):42-46. Not about consequences of testing. [pmid: 10569222].
Hansson T, Anneren G, Sjoberg O, et al. Celiac disease in relation to immunologic serum markers, trace elements, and HLA-DR and DQ antigens in Swedish children with Down syndrome. J Pediatr Gastroenterol Nutr. 1999;29(3):286-292. Not about consequences of testing. [pmid: 10467993].
Hansson T, Dahlbom I, Hall J, et al. Antibody reactivity against human and guinea pig tissue transglutaminase in children with celiac disease. J Pediatr Gastroenterol Nutr. 2000;30(4):379-384. Not about consequences of testing. [pmid: 10776947].
Hansson T, Dannaeus A, Kraaz W, et al. Production of antibodies to gliadin by peripheral blood lymphocytes in children with celiac disease: the use of an enzyme-linked immunospot technique for screening and follow-up. Pediatr Res. 1997;41(4 Pt 1):554-559. Not about consequences of testing. [pmid: 9098859].
Hansson Tony, Dahlbom Ingrid, Rogberg Siv, et al. Recombinant human tissue transglutaminase for diagnosis and follow-up of childhood coeliac disease. Pediatr Res. 2002;51(6):700-705. Not about consequences of testing. [pmid: 12032264].
Hanukoglu A, Mizrachi A, Dalal I, et al. Extrapancreatic autoimmune manifestations in type 1 diabetes patients and their first-degree relatives: A multicenter study. Diabetes Care. 2003;26(4):1235-1240. Not about consequences of testing. [pmid: 12663603].
Harper G D, Wheeler D C, Wicks A C B. Butterfat absorption - a valuable screening test in malabsorption. Postgrad Med J. 1994;70(819):23-26. Not about consequences of testing. [pmid: 8140013].
Harvey Richard F, Shaw Ian S. Current thinking in coeliac disease. Br J Gen Pract. 2002;246(1638):596-602. Not about consequences of testing.
Haycock G B. Screening test for coeliac disease. Arch Dis Child. 1976;51(5):401. Not about consequences of testing. [pmid: 938087].
Healy D A, Neumyer M M, Atnip R G, et al. Evaluation of celiac and mesenteric vascular disease with duplex ultrasonography. Journal of Ultrasound in Medicine - Official Journal of the American Institute of Ultrasound in Medicine. 1992;11(9):481-485. Not about consequences of testing. [pmid: 1491433].
Heikkinen M, Janatuinen E, Mayo K, et al. Usefulness of anti-Helicobacter pylori and anti-CagA antibodies in the selection of patients for gastroscopy. Am J Gastroenterol. 1997;92(12):2225-2229. Not about consequences of testing. [pmid: 9399758].
Heikkinen M, Pikkarainen P, Takala J, et al. Etiology of dyspepsia: four hundred unselected consecutive patients in general practice. Scand J Gastroenterol. 1995;30(6):519-523. Not about consequences of testing. [pmid: 7569757].
Heneghan M A, Mchugh P, Stevens F M, et al. Addison's disease and selective IgA deficiency in two coeliac patients. Scand J Gastroenterol. 1997;32(5):509-511. Not about consequences of testing. [pmid: 9175216].
Henker J, Zugehor M, Morrenz J. Reticulin antibodies in coeliac disease. Acta Paediatr Hung. 1983;24(4):349-353. Not about consequences of testing. [pmid: 6370277].
Hennessy W B, Ralston M. Ileocaecal carcinoma and the coeliac syndrome. Gut. 1969;10(11):951-952. Not about consequences of testing. [pmid: 5358594].
Hernandez M A, Colina G, Ortigosa L. Epilepsy, cerebral calcifications and clinical or subclinical coeliac disease. Course and follow up with gluten-free diet. Seizure. 1998;7(1):49-54. Not about consequences of testing. [pmid: 9548226].
Hertervig E, Wieslander J, Johansson C, et al. Anti-neutrophil cytoplasmic antibodies in chronic inflammatory bowel disease. Prevalence and diagnostic role. Scand J Gastroenterol. 1995;30(7):693-698. Not about consequences of testing. [pmid: 7481534].
Hill I, Fasano A, Schwartz R, et al. The prevalence of celiac disease in at-risk groups of children in the United States. Eur J Pediatr. 2000;136(1):86-90. Not about consequences of testing.
Hill Ivor D, Bhatnagar Shinjini, Cameron Donald J S, et al. Celiac disease: Working Group Report of the First World Congress of Pediatric Gastroenterology, Hepatology, and Nutrition. J Pediatr Gastroenterol Nutr. 2002;35(Suppl 2):78-88. Not about consequences of testing. [pmid: 12192175].
Hill P G, Thompson S P, Holmes G K. IgA anti-gliadin antibodies in adult celiac disease. Clin Chem. 1991;37(5):647-650. Not about consequences of testing. [pmid: 2032317].
Hill R E, Durie P R, Gaskin K J, et al. Steatorrhea and pancreatic insufficiency in Shwachman syndrome. Gastroenterology. 1982;83(1 Pt 1):22-27. Not about consequences of testing. [pmid: 7075943].
Hin H, Bird G, Fisher P, et al. Coeliac disease in primary care: case finding study. BMJ. 1999;318(7177):164-167. Not about consequences of testing. [pmid: 9888912]. [pmcid: 27697].
Hjelt K, Krasilnikoff P A. The impact of gluten on haematological status, dietary intakes of haemopoietic nutrients and vitamin B12 and folic acid absorption in children with coeliac disease. Acta Paediatr Scand. 1990;79(10):911-919. Not about consequences of testing. [pmid: 2267921].
Hoey John. Irritable bowel syndrome: could it be celiac disease?. Cmaj - Canadian Medical Association Journal = Journal De L'association Medicale Canadienne. 2002;166(4):479-480. Not about consequences of testing.
Hoffbrand A V. Anaemia in adult coeliac disease. Clin Gastroenterol. 1974;3(1):71-89. Not about consequences of testing. [pmid: 4599262].
Hoffenberg E J, Bao F, Eisenbarth G S, et al. Transglutaminase antibodies in children with a genetic risk for celiac disease. Eur J Pediatr. 2000;137(3):356-360. Not about consequences of testing.
Hoffenberg E J, Haas J, Drescher A, et al. A trial of oats in children with newly diagnosed celiac disease. Eur J Pediatr. 2000;137(3):361-366. Not about consequences of testing.
Hogberg L, Falth-Magnusson K, Grodzinsky E, et al. Familial prevalence of coeliac disease: A twenty-year follow-up study. Scand J Gastroenterol. 2003;38(1):61-65. Not about consequences of testing. [pmid: 12608466].
Holdstock G, Eade O E, Isaacson P, et al. Endoscopic duodenal biopsies in coeliac disease and duodenitis. Scand J Gastroenterol. 1979;14(6):717-720. Not about consequences of testing. [pmid: 531504].
Holdstock G. Jejunal biopsy without the need for screening. Lancet. 1978;1(8076):1236-1237. Not about consequences of testing. [pmid: 77999].
Holmes G K T. Coeliac disease and malignancy. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(3):229-237. Not about consequences of testing. [pmid: 11990397].
Holmes G K T. Screening for coeliac disease in type 1 diabetes. Arch Dis Child. 2002;87(6):495-498. Not about consequences of testing. [pmid: 12456547].
Holmes G K. Coeliac disease and Type 1 diabetes mellitus - the case for screening. Diabet Med. 2001;18(3):169-177. Not about consequences of testing. [pmid: 11318836].
Holmes G K. Non-malignant complications of coeliac disease. Acta Paediatr. 1996;412(Suppl):68-75. Not about consequences of testing.
Holt Peter R. Gastrointestinal diseases in the elderly. Curr Opin Clin Nutr Metab Care. 2003;6(1):41-48. Not about consequences of testing. [pmid: 12496680].
Holt Worthe S. Factors affecting compliance with screening sigmoidoscopy. J Fam Pract. 1991;32(6):585-589. Not about consequences of testing. [pmid: 2040883].
Horvath K, Mehta D I. Celiac disease--a worldwide problem. Indian J Pediatr. 2000;67(10):757-763. Not about consequences of testing. [pmid: 11105427].
Horvath Karoly, Hill Ivor D. Anti-tissue transglutaminase antibody as the first line screening for celiac disease: good-bye antigliadin tests?. Am J Gastroenterol. 2002;97(11):2702-2704. Not about consequences of testing. [pmid: 12425536].
Hourihane D O, Weir D G. Malignant celiac syndrome. Report of two cases with malabsorption and microscopic foci of intestinal lymphoma. Gastroenterology. 1970;59(1):130-139. Not about consequences of testing. [pmid: 5426983].
Hovell C J, Collett J A, Vautier G, et al. High prevalence of coeliac disease in a population-based study from Western Australia: a case for screening?. Med J Aust. 2001;175(5):247-250. Not about consequences of testing. [pmid: 11587254].
Howard M R, Turnbull A J, Morley P, et al. A prospective study of the prevalence of undiagnosed coeliac disease in laboratory defined iron and folate deficiency. J Clinl Path. 2002;55(10):754-757. Not about consequences of testing.
Hulse J A. Referral criteria for growth screening. J Med Screen. 1995;2(3):168-170. Not about consequences of testing. [pmid: 8536190].
Hummel M, Bonifacio E, Stern M, et al. Development of celiac disease-associated antibodies in offspring of parents with type I diabetes. Diabetologia. 2000;43(8):1005-1011. Not about consequences of testing. [pmid: 10990078].
Hurley T H, Sullivan J R, Hurley J V. Reaction to Kveim test material in sarcoidosis and other diseases. Lancet. 1975;1(7905):494-496. Not about consequences of testing. [pmid: 46962].
Hyams J S, Treem W R, Justinich C J, et al. Characterization of symptoms in children with recurrent abdominal pain: resemblance to irritable bowel syndrome. J Pediatr Gastroenterol Nutr. 1995;20(2):209-214. Not about consequences of testing. [pmid: 8583293].
Hyer W, Cotterill A M, Savage M O. Common causes of short stature detectable by a height surveillance programme. J Med Screen. 1995;2(3):150-153. Not about consequences of testing. [pmid: 8536185].
Iacono G, Carroccio A, Montalto G, et al. Steatocrit test after a standard fatty meal: a new simple and sensitive test to detect malabsorption. J Pediatr Gastroenterol Nutr. 1991;13(2):161-167. Not about consequences of testing. [pmid: 1941409].
Iacono G, Carroccio A, Montalto G, et al. Steatocrit test: normal range and physiological variations in preterm and low-birth-weight full-term newborns. Acta Paediatr. 1992;81(11):933-934. Not about consequences of testing. [pmid: 1467618].
Iancu T, Elian E. The intestinal microvillus Ultrastructural variability in coeliac disease and cow's milk intolerance. Acta Paediatr Scand. 1976;65(1):65-73. Not about consequences of testing. [pmid: 1251726].
Iglesias S, Chapon F, Baron J C. Familial occipital calcifications, hemorrhagic strokes, leukoencephalopathy, dementia, and external carotid dysplasia. Neurology. 2000;55(11):1661-1667. Not about consequences of testing. [pmid: 11113220].
Iovino P, Ciacci C, Sabbatini F, et al. Esophageal impairment in adult celiac disease with steatorrhea. Am J Gastroenterol. 1998;93(8):1243-1249. Not about consequences of testing. [pmid: 9707045].
Ivarsson A, Persson L A, Juto P, et al. High prevalence of undiagnosed coeliac disease in adults: a Swedish population-based study. J Intern Med. 1999;245(1):63-68. Not about consequences of testing. [pmid: 10095818].
Ivarsson S A, Carlsson A, Bredberg A, et al. Prevalence of coeliac disease in Turner syndrome. Acta Paediatr. 1999;88(9):933-936. Not about consequences of testing. [pmid: 10519331].
Jaeger C, Hatziagelaki E, Petzoldt R, et al. Comparative analysis of organ-specific autoantibodies and celiac disease--associated antibodies in type 1 diabetic patients, their first-degree relatives, and healthy control subjects. Diabetes Care. 2001;24(1):27-32. Not about consequences of testing. [pmid: 11194235].
James M W, Scott B B. Evidence-based clinical medicine: Application of a diagnostic test using the example of coeliac disease. Cme J Gastroenterol Hepatol Nutr. 2001;4(1):28-31. Unable to obtain article.
Janatkova I, Malic caron, Fu caron, et al. Diagnostic asset of assessment of autoantibodies in gluten-sensitive enteropathy. Epidemiol Mikrobiol Imunol. 2002;51(3):125-130. Not about consequences of testing. [pmid: 12184191].
Janatuinen E K, Kemppainen T A, Julkunen R J K, et al. No harm from five year ingestion of oats in coeliac disease. Gut. 2002;50(3):332-335. Not about consequences of testing. [pmid: 11839710]. [pmcid: 1773136].
Jansson U H, Gudjonsdottir A H, Ryd W, et al. Two different doses of gluten show a dose-dependent response of enteropathy but not of serological markers during gluten challenge in children with coeliac disease. Acta Paediatr. 2001;90(3):255-259. Not about consequences of testing. [pmid: 11332163].
Jansson Ulf H G, Kristiansson Bengt, Albertsson-Wikland Kerstin, et al. Short-term gluten challenge in children with coeliac disease does not impair spontaneous growth hormone secretion. J Pediatr Endocrinol Metab. 2003;16(5):771-778. Not about consequences of testing. [pmid: 12880127].
Jaskowski T D, Schroder C, Martins T B, et al. IgA antibodies against endomysium and transglutaminase: a comparison of methods. J Clin Lab Anal. 2001;15(3):108-111. Not about consequences of testing. [pmid: 11344523].
Jennings J S R, Howdle P D. Celiac disease. Curr Opin Gastroenterol. 2001;17(2):118-126. Not about consequences of testing. [pmid: 11224666].
Johansen B H, Gjertsen H A, Vartdal F, et al. Binding of peptides from the N-terminal region of alpha-gliadin to the celiac disease-associated HLA-DQ2 molecule assessed in biochemical and T cell assays. Clin Immunol Immunopathol. 1996;79(3):288-293. Not about consequences of testing. [pmid: 8635288].
Johnson R E, Green T A, Schachter J, et al. Evaluation of nucleic acid amplification tests as reference tests for Chlamydia trachomatis infections in asymptomatic men. J Clin Microbiol. 2000;38(12):4382-4386. Not about consequences of testing. [pmid: 11101568]. [pmcid: 87609].
Johnston S D, Peter Watson R G, McMillan S A. Soda bread provocation test for subjects with transient serology for coeliac disease 3 years after a population screening survey. Eur J Gastroenterol Hepatol. 2000;12(9):1013-1015. Not about consequences of testing. [pmid: 11007138].
Johnston S D, Ritchie C, Robinson J. Application of red cell distribution width to screening for coeliac disease in insulin-dependent diabetes mellitus. Ir J Med Sci. 1999;168(3):167-170. Not about consequences of testing. [pmid: 10540781].
Johnston S D, Smye M, Watson R G P, et al. Lactulose-mannitol intestinal permeability test: A useful screening test for adult coeliac disease. Ann Clin Biochem. 2000;37(4):512-519. Not about consequences of testing. [pmid: 10902869].
Johnston S D, Smye M, Watson R P. Intestinal permeability tests in coeliac disease. Clin Lab. 2001;47(34):143-150. Not about consequences of testing. [pmid: 11294577].
Johnston S D, Watson R G P. Small bowel lymphoma in unrecognized coeliac disease: A cause for concern?. Eur J Gastroenterol Hepatol. 2000;12(6):645-648. Not about consequences of testing. [pmid: 10912485].
Johnston S D, Watson R G, McMillan S A, et al. Preliminary results from follow-up of a large-scale population survey of antibodies to gliadin, reticulin and endomysium. Acta Paediatr. 1996;412(Suppl):61-64. Not about consequences of testing.
Johnston S D, Watson R G, McMillan S A, et al. Serological markers for coeliac disease: changes with time and relationship to enteropathy. Eur J Gastroenterol Hepatol. 1998;10(3):259-264. Not about consequences of testing. [pmid: 9585032].
Johnston S D, Watson R G, Middleton D, et al. Genetic, morphometric and immunohistochemical markers of latent coeliac disease. Eur J Gastroenterol Hepatol. 1999;11(11):1283-1288. Not about consequences of testing. [pmid: 10563541].
Johnston Simon D, McMillan Stanley A, Collins John S, et al. A comparison of antibodies to tissue transglutaminase with conventional serological tests in the diagnosis of coeliac disease. Eur J Gastroenterol Hepatol. 2003;15(9):1001-1004. Not about consequences of testing. [pmid: 12923373].
Johnstone D E. Food allergy in children under two years of age. Pediatr Clin North Am. 1969;16(1):211-216. Not about consequences of testing. [pmid: 4885826].
Jokinen J, Peters U, Maki M, et al. Celiac sprue in patients with chronic oral mucosal symptoms. J Clin Gastroenterol. 1998;26(1):23-26. Not about consequences of testing. [pmid: 9492858].
Juby L D, Rothwell J, Axon A T. Lactulose/mannitol test: an ideal screen for celiac disease. Gastroenterology. 1989;96(1):79-85. Not about consequences of testing. [pmid: 2491824].
Juto P, Fredrikzon B, Hernell O. Gliadin-specific serum immunoglobulins A, E, G, and M in childhood: relation to small intestine mucosal morphology. J Pediatr Gastroenterol Nutr. 1985;4(5):723-729. Not about consequences of testing. [pmid: 4045630].
Kalapesi Z, Rees J P R. Coeliac disease in schoolchildren. Ir Med J. 1978;71(6):188-191. Not about consequences of testing. [pmid: 649327].
Kallikorm R, Uibo O, Uibo R. Coeliac disease in spondyloarthropathy: usefulness of serological screening. Clin Rheumatol. 2000;19(2):118-122. Not about consequences of testing. [pmid: 10791622].
Kapadia C. The reliability of noninvasive tests for celiac disease. Gastroenterology. 1995;108(2):608-610. Not about consequences of testing. [pmid: 7557159].
Kapuscinska A, Zalewski T, Chorzelski T P, et al. Disease specificity and dynamics of changes in IgA class anti-endomysial antibodies in celiac disease. J Pediatr Gastroenterol Nutr. 1987;6(4):529-534. Not about consequences of testing. [pmid: 3323442].
Karczewska K, Lukasik M, Kasner J, et al. Familial occurrence of celiac disease and isolated immunoglobulin a deficiency. Med Sci Monit. 1998;4(5):836-839. Not about consequences of testing.
Katz A J, Falchuk Z M. Current concepts in gluten sensitive enteropathy (celiac sprue). Pediatr Clin North Am. 1975;22(4):767-785. Not about consequences of testing. [pmid: 1105361].
Kaukinen K, Collin P, Holm K, et al. Small-bowel mucosal inflammation in reticulin or gliadin antibody-positive patients without villous atrophy. Scand J Gastroenterol. 1998;33(9):944-949. Not about consequences of testing. [pmid: 9759950].
Kaukinen K, Collin P, Holm K, et al. Wheat starch-containing gluten-free flour products in the treatment of coeliac disease and dermatitis herpetiformis. A long-term follow-up study. Scand J Gastroenterol. 1999;34(2):163-169. Not about consequences of testing. [pmid: 10192194].
Kaukinen K, Halme L, Collin P, et al. Celiac disease in patients with severe liver disease: Gluten-free diet may reverse hepatic failure. Gastroenterology. 2002;122(4):881-888. Not about consequences of testing. [pmid: 11910339].
Kaukinen Katri, Partanen Jukka, Maki Markku, et al. HLA-DQ typing in the diagnosis of celiac disease. Am J Gastroenterol. 2002;97(3):695-699. Not about consequences of testing. [pmid: 11922565].
Kaukinen Katri, Sulkanen Satu, Maki Markku, et al. IgA-class transglutaminase antibodies in evaluating the efficacy of gluten-free diet in coeliac disease. Eur J Gastroenterol Hepatol. 2002;14(3):311-315. Not about consequences of testing. [pmid: 11953698].
Kawasaki E, Eisenbarth G S. High-throughput radioassays for autoantibodies to recombinant autoantigens. Front Biosci 2000;5181–190. Not about consequences of testing
Kelly C P, Feighery C F, Gallagher R B, et al. Mucosal and systemic IgA anti-gliadin antibody in celiac disease. Contrasting patterns of response in serum, saliva, and intestinal secretions. Dig Dis Sci. 1991;36(6):743-751. Not about consequences of testing. [pmid: 2032515].
Kelly J, O'Farrelly C, Rees J P, et al. Humoral response to alpha gliadin as serological screening test for coeliac disease. Arch Dis Child. 1987;62(5):469-473. Not about consequences of testing. [pmid: 3606179].
Kelly J, Whelan C A, Weir D G, et al. Removal of endogenous peroxidase activity from cryostat sections for immunoperoxidase visualisation of monoclonal antibodies. J Immunol Methods. 1987;96(1):127-132. Not about consequences of testing. [pmid: 3100646].
Kennedy N P, Feighery C. Clinical features of coeliac disease today. Biomed Pharmacother. 2000;54(7):373-380. Not about consequences of testing. [pmid: 10989976].
Kerlin P, Wong L. Breath hydrogen testing in bacterial overgrowth of the small intestine. Gastroenterology. 1988;95(4):982-988. Not about consequences of testing. [pmid: 3410238].
Khoshoo V, Bhan M K, Unsworth D J, et al. Anti-reticulin antibodies: useful adjunct to histopathology in diagnosing celiac disease, especially in a developing country. J Pediatr Gastroenterol Nutr. 1988;7(6):864-866. Not about consequences of testing. [pmid: 3143820].
Khuffash F A, Barakat M H, Shaltout A A, et al. Coeliac disease among children in Kuwait: difficulties in diagnosis and management. Gut. 1987;28(12):1595-1599. Not about consequences of testing. [pmid: 3428686]. [pmcid: 1433935].
Kieffer M. Serum antibodies to gliadin and other cereal proteins in patients with coeliac disease and dermatitis herpetiformis. Dan Med Bull. 1985;32(5):251-262. Not about consequences of testing. [pmid: 4053695].
Kieslich M, Errazuriz G, Posselt H G, et al. Brain white-matter lesions in celiac disease: a prospective study of 75 diet-treated patients. Pediatrics. 2001;108(2):E21. Not about consequences of testing. [pmid: 11483831].
Kilander A F, Dotevall G, Fallstrom S P, et al. Evaluation of gliadin antibodies for detection of coeliac disease. Scand J Gastroenterol. 1983;18(3):377-383. Not about consequences of testing. [pmid: 6673063].
King A L, Fraser J S, Moodie S J, et al. Coeliac disease: follow-up linkage study provides further support for existence of a susceptibility locus on chromosome 11p11. Ann Hum Genet. 2001;65(Pt 4):377-386. Not about consequences of testing. [pmid: 11592927].
Kingham J G, Parker D R. The association between primary biliary cirrhosis and coeliac disease: a study of relative prevalences. Gut. 1998;42(1):120-122. Not about consequences of testing. [pmid: 9577357]. [pmcid: 1726939].
Klasen E C, Polanco I, Biemond I, et al. alpha 1-Antitrypsin and coeliac disease in spain. Gut. 1980;21(11):948-950. Not about consequences of testing. [pmid: 6969683]. [pmcid: 1419289].
Knivsberg A M. Urine patterns, peptide levels and IgA/IgG antibodies to food proteins in children with dyslexia. Pediatr Rehabil. 1997;1(1):25-33. Not about consequences of testing. [pmid: 9689235].
Kocna Petr, Vanickova Zdislava, Perusicova Jindriska, et al. Tissue transglutaminase-serology markers for coeliac disease. Clin Chem Lab Med. 2002;40(5):485-492. Not about consequences of testing. [pmid: 12113293].
Kokkonen J, Viitanen A, Simila S. Coping with a coeliac diet after adolescence. Helv Paediatr Acta. 1989;43(4):261-265. Unable to obtain article. [pmid: 2708068].
Kolek A, Fischerova E, Kos V et al. Application of ELISA method to determine antigliadin antibodies in children with coeliac disease. Acta Univ Palacki Olomuc Fac Med 1989;122183–192. Not about consequences of testing
Kolek A, Vospelova J, Hermanova Z, et al. Occurrence of Coeliac Disease in Children With Down Syndrome in North Moravia, Czech Republic. Eur J Pediatr. 2003;162(3):207-208. Not about consequences of testing. [pmid: 12655432].
Koletzko S, Burgin-Wolff A, Koletzko B, et al. Prevalence of coeliac disease in diabetic children and adolescents. A multicentre study. Eur J Pediatr. 1988;148(2):113-117. Not about consequences of testing. [pmid: 3069470].
Kolho K L, Farkkila M A, Savilahti E. Undiagnosed coeliac disease is common in Finnish adults. Scand J Gastroenterol. 1998;33(12):1280-1283. Not about consequences of testing. [pmid: 9930391].
Kolho K L, Jusufovic J, Miettinen A, et al. Parietal cell antibodies and Helicobacter pylori in children. J Pediatr Gastroenterol Nutr. 2000;30(3):265-268. Not about consequences of testing. [pmid: 10749409].
Kolho K L, Savilahti E. IgA endomysium antibodies on human umbilical cord: an excellent diagnostic tool for celiac disease in childhood. J Pediatr Gastroenterol Nutr. 1997;24(5):563-567. Not about consequences of testing. [pmid: 9161953].
Kolho K L, Tiitinen A, Tulppala M, et al. Screening for coeliac disease in women with a history of recurrent miscarriage or infertility. Br J Obstet Gynaecol. 1999;106(2):171-173. Not about consequences of testing. [pmid: 10426684].
Kolsteren M M, Koopman H M, Schalekamp G, et al. Health-related quality of life in children with celiac disease. Eur J Pediatr. 2001;138(4):593-595. Not about consequences of testing.
Koop I, Ilchmann R, Izzi L, et al. Detection of autoantibodies against tissue transglutaminase in patients with celiac disease and dermatitis herpetiformis. Am J Gastroenterol. 2000;95(8):2009-2014. Not about consequences of testing. [pmid: 10950050].
Korponay-Szabo I R, Kovacs J B, Czinner A, et al. High prevalence of silent celiac disease in preschool children screened with IgA/IgG antiendomysium antibodies. J Pediatr Gastroenterol Nutr. 1999;28(1):26-30. Not about consequences of testing. [pmid: 9890464].
Korponay-Szabo I R, Kovacs J B, Lorincz M, et al. Prospective significance of antiendomysium antibody positivity in subsequently verified celiac disease. J Pediatr Gastroenterol Nutr. 1997;25(1):56-63. Not about consequences of testing. [pmid: 9226528].
Korponay-Szabo I, Kovacs J, Lorincz M, et al. Families with multiple cases of gluten-sensitive enteropathy. Z Gastroenterol. 1998;36(7):553-558. Not about consequences of testing. [pmid: 9738302].
Kotze L M, Utiyama S R, Nisihara R M, et al. Antiendomysium antibodies in Brazilian patients with celiac disease and their first-degree relatives. Arq Gastroenterol. 2001;38(2):94-103. Not about consequences of testing. [pmid: 11793949].
Kowalska E, Wasowska-Krolikowska K, Toporowska-Kowalska E. Estimation of antithyroid antibodies occurrence in children with coeliac disease. Medical Science Monitor - International Medical Journal of Experimental and Clinical Research. 2000;6(4):719-721. Not about consequences of testing. [pmid: 11208398].
Kowlessar O D, Phillips L D. Celiac disease. Med Clin North Am. 1970;54(3):647-656. Not about consequences of testing. [pmid: 5423138].
Krasilnikoff P A, Gudman-Hoyer E, Moltke H H. Diagnostic value of disaccharide tolerance tests in children. Acta Paediatr Scand. 1975;64(5):693-698. Not about consequences of testing. [pmid: 1166789].
Krawitt E L, Chastenay B F. 25-hydroxy vitamin D absorption test in patients with gastrointestinal disorders. Calcif Tissue Int. 1980;32(3):183-187. Not about consequences of testing. [pmid: 6775786].
Kristiansson B, Karlberg J, Fallstrom S P. Infants with low rate of weight gain. I. A study of organic factors and growth patterns. Acta Paediatr Scand. 1981;70(5):655-662. Not about consequences of testing. [pmid: 7324913].
Kugathasan S, Czinn S J. Gastroduodenal inflammation and related disorders in children. Curr Opin Gastroenterol. 1996;12(6):537-543. Not about consequences of testing.
Kuitunen P, Kosnai I, Savilahti E. Morphometric study of the jejunal mucosa in various childhood enteropathies with special reference to intraepithelial lymphocytes. J Pediatr Gastroenterol Nutr. 1982;1(4):525-531. Not about consequences of testing. [pmid: 7186067].
Kull K, Uibo O, Salupere R, et al. High frequency of antigliadin antibodies and absence of antireticulin and antiendomysium antibodies in patients with ulcerative colitis. J Gastroenterol. 1999;34(1):61-65. Not about consequences of testing. [pmid: 10204612].
Kumar P J, Walker-Smith J, Milla P, et al. The teenage coeliac: follow up study of 102 patients. Arch Dis Child. 1988;63(8):916-920. Not about consequences of testing. [pmid: 3415327].
Kumar P J. European and North American populations should be screened for coeliac disease. Gut. 2003;52(2):170-171. Not about consequences of testing. [pmid: 12692052]. [pmcid: 1774950].
Kumar Rajesh, Eastwood Amy L, Brown Milton L, et al. Human genome search in celiac disease: mutated gliadin T-cell-like epitope in two human proteins promotes T-cell activation. J Mol Biol. 2002;319(3):593-602. Not about consequences of testing. [pmid: 12054857].
Kumar V, Jarzabek-Chorzelska M, Sulej J, et al. Tissue transglutaminase and endomysial antibodies-diagnostic markers of gluten-sensitive enteropathy in dermatitis herpetiformis. Clin Immunol. 2001;98(3):378-382. Not about consequences of testing. [pmid: 11237562].
Kumar V, Rajadhyaksha M, Wortsman J. Celiac disease-associated autoimmune endocrinopathies. Clin Diagn Lab Immunol. 2001;8(4):678-685. Not about consequences of testing. [pmid: 11427410]. [pmcid: 96126].
Kushnir Talma, Rabinowitz Stanley, Melamed Samuel, et al. Health responsibility and workplace health promotion among women: Early detection of cancer. Health Care Women Int. 1995;16(4):329-340. Not about consequences of testing. [pmid: 7649890].
La Seta F, Salerno G, Buccellato A, et al. Radiographic indicants of adult celiac disease assessed by double-contrast small bowel enteroclysis. Eur J Radiol. 1992;15(2):157-162. Not about consequences of testing. [pmid: 1425755].
Labate A, Gambardella A, Messina D, et al. Silent celiac disease in patients with childhood localization-related epilepsies. Epilepsia. 2001;42(9):1153-1155. Not about consequences of testing. [pmid: 11580763].
Labib M, Gama R, Marks V. Predictive value of D-xylose absorption test and erythrocyte folate in adult coeliac disease: a parallel approach. Ann Clin Biochem. 1990;27(Pt 1):75-77. Not about consequences of testing. [pmid: 2310161].
Lad R, Jacobson K. The changing face of celiac disease. Paediatr Child Health. 2001;6(9):644-651. Not about consequences of testing. [pmid: 20084136].
Ladinser B, Rossipal E, Pittschieler K. Endomysium antibodies in coeliac disease: an improved method. Gut. 1994;35(6):776-778. Not about consequences of testing. [pmid: 8020804]. [pmcid: 1374877].
Lagerqvist C, Ivarsson A, Juto P, et al. Screening for adult coeliac disease - which serological marker(s) to use?. J Intern Med. 2001;250(3):241-248. Not about consequences of testing. [pmid: 11555129].
Lahat E, Broide E, Leshem M, et al. Prevalence of celiac antibodies in children with neurologic disorders. Pediatr Neurol. 2000;22(5):393-396. Not about consequences of testing. [pmid: 10913732].
Lahteenoja H, Maki M, Viander M, et al. Local challenge of oral mucosa with gliadin in patients with coeliac disease. Clin Exp Immunol. 2000;120(1):38-45. Not about consequences of testing. [pmid: 10759761]. [pmcid: 1905618].
Lahteenoja H, Maki M, Viander M, et al. Local challenge on oral mucosa with an alpha-gliadin related synthetic peptide in patients with celiac disease. Am J Gastroenterol. 2000;95(10):2880-2887. Not about consequences of testing. [pmid: 11051363].
Lahteenoja H, Toivanen A, Raiha I, et al. Salivary antigliadin and antiendomysium antibodies in coeliac disease. Scand J Immunol. 1999;50(5):528-535. Not about consequences of testing. [pmid: 10564556].
Lamabadusuriya S P, Packer S, Harries J T. Limitations of xylose tolerance test as a screening procedure in childhood coeliac disease. Arch Dis Child. 1975;50(1):34-39. Not about consequences of testing. [pmid: 1124941].
Lamabadusuriya S P, Packer S, Harries J T. Proceedings: Limitations of xylose tolerance test as screening procedure for coeliac disease. Arch Dis Child. 1974;49(3):244-245. Not about consequences of testing. [pmid: 4825637].
Lamontagne P, West G E, Galibois I. Quebecers with celiac disease: analysis of dietary problems. Canadian Journal of Dietetic Practice and Research - a Publication of Dietitians of Canada = Revue Canadienne De La Pratique Et De La Recherche En Dietetique - Une Publication Des Dietetistes Du C. 2001;62(4):175-181. Not about consequences of testing.
Lampasona V, Bazzigaluppi E, Barera G, et al. Tissue transglutaminase and combined screening for coeliac disease and type 1 diabetes-associated autoantibodies. Lancet. 1998;352(9135):1192-1193. Not about consequences of testing. [pmid: 9777840].
Lang-Muritano M, Molinari L, Dommann-Scherrer C, et al. Incidence of enteropathy-associated T-cell lymphoma in celiac disease: Implications for children and adolescents with type 1 diabetes. Pediatr Diabetes. 2002;3(1):42-45. Not about consequences of testing. [pmid: 15016174].
Lankisch P G, Martinez Schramm A, Petersen F, et al. Diagnostic intervals for recognizing celiac disease. Z Gastroenterol. 1996;34(8):473-477. Not about consequences of testing. [pmid: 8794542].
Lapini M, Lasagni D, Ferrari R. Detection of anti-smooth muscle antibodies in the sera of patients with celiac disease: Relationship with anti-endomysium antibodies. Eur J Lab Med. 1998;6(3):174-176. Not about consequences of testing.
Larcher V F, Shepherd R, Francis D E, et al. Protracted diarrhoea in infancy. Analysis of 82 cases with particular reference to diagnosis and management. Arch Dis Child. 1977;52(8):597-605. Not about consequences of testing. [pmid: 579080].
Larizza D, Calcaterra V, De Giacomo C, et al. Celiac disease in children with autoimmune thyroid disease. Eur J Pediatr. 2001;139(5):738-740. Not about consequences of testing.
Larizza D, Calcaterra V, Luinetti O, et al. Evidence for immunogenetic predisposition in children with celiac disease and autoimmune thyroid disease. Int J Med Biol Environ. 2001;29(2):143-148. Not about consequences of testing.
Lasagni D, Ferrari R, Lapini M. Unmasking anti-endomysial antibodies in coeliac subjects positive for anti-smooth muscle antibodies. Acta Paediatr. 1999;88(4):462-464. Not about consequences of testing. [pmid: 10342549].
Lavy U, Bauer C H. Pathophysiology of failure to thrive in gastrointestinal disorders. Pediatr Ann. 1978;7(11):743-749. Not about consequences of testing. [pmid: 740423].
Lazzari R, Volta U, Bianchi F B, et al. R1 reticulin antibodies: markers of celiac disease in children on a normal diet and on gluten challenge. J Pediatr Gastroenterol Nutr. 1984;3(4):516-522. Not about consequences of testing. [pmid: 6384456].
Lebenthal E, Branski D. Childhood celiac disease--a reappraisal. Eur J Pediatr. 1981;98(5):681-690. Not about consequences of testing.
Lebenthal E, Heitlinger L A. Gliadin antibodies in celiac disease. Eur J Pediatr. 1983;102(5):711-712. Not about consequences of testing.
Lebenthal Emanuel, Branski David. Celiac disease: an emerging global problem. J Pediatr Gastroenterol Nutr. 2002;35(4):472-474. Not about consequences of testing. [pmid: 12394370].
Lebenthal Emanuel, Branski David. Serum anti-endomysial and anti-tissue transglutaminase for screening of celiac disease. Isr Med Assoc J. 2002;4(8):627-628. Not about consequences of testing. [pmid: 12183869].
Lee M F. The diagnosis of steatorrhoea in outpatients. Br J Surg. 1970;57(5):387-388. Not about consequences of testing. [pmid: 4193530].
Lee Susie K, Lo Winson, Memeo Lorenzo, et al. Duodenal histology in patients with celiac disease after treatment with a gluten-free diet. Gastrointest Endosc. 2003;57(2):187-191. Not about consequences of testing. [pmid: 12556782].
Lejarraga H, Caino S, Salvador A, et al. Normal growth velocity before diagnosis of celiac disease. J Pediatr Gastroenterol Nutr. 2000;30(5):552-556. Not about consequences of testing. [pmid: 10817287].
Lembcke B, Grimm K, Lankisch P G. Raised fecal fat concentration is not a valid indicator of pancreatic steatorrhea. Am J Gastroenterol. 1987;82(6):526-531. Not about consequences of testing. [pmid: 3646827].
Lenihan Genie O, Kirk William G. Conjoint supervision with beginning trainees: The model and its effectiveness. Clinical Supervisor. 1992;10(1):35-50. Not about consequences of testing.
Leon F, Camarero C, Pena R, et al. Anti-transglutaminase IgA ELISA: clinical potential and drawbacks in celiac disease diagnosis. Scand J Gastroenterol. 2001;36(8):849-853. Not about consequences of testing. [pmid: 11495081].
Lepore L, Martelossi S, Pennesi M, et al. Prevalence of celiac disease in patients with juvenile chronic arthritis. Eur J Pediatr. 1996;129(2):311-313. Not about consequences of testing.
Lepore L, Pennesi M, Ventura A, et al. Anti-alpha-gliadin antibodies are not predictive of celiac disease in juvenile chronic arthritis. Acta Paediatr. 1993;82(67):569-573. Not about consequences of testing. [pmid: 8338992].
Lerman Caryn, Trock Bruce, Rimer Barbara K, et al. Psychological side effects of breast cancer screening. Health Psychol. 1991;10(4):259-267. Not about consequences of testing. [pmid: 1915212].
Lerner A. The race for the diagnostic autoantibody in celiac disease. And the winner is…. Isr Med Assoc J. 2000;2(2):82-83. Not about consequences of testing. [pmid: 11344731].
Leshowitz Barry, Meyers Jonathan M. Application of decision theory to DUI assessment. Alcohol Clin Exp Res. 1996;20(7):1148-1152. Not about consequences of testing. [pmid: 8904962].
Levine A, Bujanover Y, Reif S, et al. Comparison of assays for anti-endomysial and anti-transglutaminase antibodies for diagnosis of pediatric celiac disease. Isr Med Assoc J. 2000;2(2):122-125. Not about consequences of testing. [pmid: 10804933].
Levine A, Lahav J, Zahavi I, et al. Activated protein C resistance in pediatric inflammatory bowel disease. J Pediatr Gastroenterol Nutr. 1998;26(2):172-174. Not about consequences of testing. [pmid: 9481632].
Levy-Gigi C, Mandelowitz N, Peled Y, et al. Is the fat breath test effective in the diagnosis of fat malabsorption and pancreatic disease?. Digestion. 1978;18(12):77-85. Not about consequences of testing. [pmid: 729947].
Lewis C, Book L, Black J, et al. Celiac disease and human leukocyte antigen genotype: Accuracy of diagnosis in self-diagnosed individuals, dosage effect, and sibling risk. J Pediatr Gastroenterol Nutr. 2000;31(1):22-27. Not about consequences of testing. [pmid: 10896066].
Li Voon, Chong J S W, Leong K S, et al. Is coeliac disease more prevalent in young adults with coexisting Type 1 diabetes mellitus and autoimmune thyroid disease compared with those with Type 1 diabetes mellitus alone?. Diabet Med. 2002;19(4):334-337. Not about consequences of testing. [pmid: 11943007].
Lightdale C J, Winawer S J. Screening diagnosis and staging of esophageal cancer. Semin Oncol. 1984;11(2):101-112. Not about consequences of testing. [pmid: 6729490].
Linaker B D, Calam J. Is jejunal biopsy valuable in the elderly?. Age Ageing. 1978;7(4):244-245. Not about consequences of testing. [pmid: 727074].
Lindgren S, Sjoberg K, Eriksson S. Unsuspected coeliac disease in chronic ‘cryptogenic’ liver disease. Scand J Gastroenterol. 1994;29(7):661-664. Not about consequences of testing. [pmid: 7939405].
Lindh E, Ljunghall S, Larsson K, et al. Screening for antibodies against gliadin in patients with osteoporosis. J Intern Med. 1992;231(4):403-406. Not about consequences of testing. [pmid: 1588266].
Lindquist B L, Rogozinski T, Moi H, et al. Endomysium and gliadin IgA antibodies in children with coeliac disease. Scand J Gastroenterol. 1994;29(5):452-456. Not about consequences of testing. [pmid: 8036461].
Lindqvist U, Rudsander A, Bostrom A, et al. IgA antibodies to gliadin and coeliac disease in psoriatic arthritis. Rheumatology (Oxford). 2002;41(1):31-37. Not about consequences of testing. [pmid: 11792877].
Littlewood J M. Coeliac disease in childhood. Bailliere's Clinical Gastroenterology. 1995;9(2):295-327. Not about consequences of testing. [pmid: 7549029].
Liu E, Bao F, Barriga K, et al. Fluctuating transglutaminase autoantibodies are related to histologic features of celiac disease. Clin Gastroenterol Hepatol. 2003;1(5):356-362. Not about consequences of testing. [pmid: 15017653].
Ljungman G, Myrdal U. Compliance in teenagers with coeliac disease--a Swedish follow-up study. Acta Paediatr. 1993;82(3):235-238. Not about consequences of testing. [pmid: 8495075].
Lloyd J K. Effects and treatment of malabsorption in childhood. Proc Nutr Soc. 1972;31(1):61-66. Not about consequences of testing. [pmid: 5048485].
Lloyd-Still J D. Chronic diarrhea of childhood and the misuse of elimination diets. Eur J Pediatr. 1979;95(1):10-13. Not about consequences of testing.
Lo Winson, Sano Kevin, Lebwohl Ben, et al. Changing presentation of adult celiac disease. Dig Dis Sci. 2003;48(2):395-398. Not about consequences of testing. [pmid: 12643621].
Lock R J, Pitcher M C, Unsworth D J. IgA anti-tissue transglutaminase as a diagnostic marker of gluten sensitive enteropathy. Am J Clin Pathol. 1999;52(4):274-277. Not about consequences of testing.
Loft D E, Marsh M N, Crowe P T. Rectal gluten challenge and diagnosis of coeliac disease. Lancet. 1990;335(8701):1293-1295. Not about consequences of testing. [pmid: 1976971].
Loft D E, Nwokolo C U, Ciclitira P J. The diagnosis of gluten sensitivity and coeliac disease--the two are not mutually inclusive. Eur J Gastroenterol Hepatol. 1998;10(11):911-913. Not about consequences of testing. [pmid: 9872611].
Loft D E. The epidemiology and diagnosis of coeliac disease. Eur J Gastroenterol Hepatol. 1993;5(2):69-72. Not about consequences of testing.
Logan A C, Wong C. Chronic fatigue syndrome: oxidative stress and dietary modifications. Altern Med Rev. 2001;6(5):450-459. Not about consequences of testing. [pmid: 11703165].
Logan R F A, Howarth G F, West J, et al. How often is a positive faecal occult blood test the result of coeliac disease?. Eur J Gastroenterol Hepatol. 2003;15(10):1097-1100. Not about consequences of testing. [pmid: 14501618].
Logan R F, Rifkind E A, Turner I D, et al. Mortality in celiac disease. Gastroenterology. 1989;97(2):265-271. Not about consequences of testing. [pmid: 2744350].
Logan R F. Screening for coeliac disease--has the time come for mass screening?. Acta Paediatr. 1996;412(Suppl):15-19. Unable to obtain article.
Longstreth George F, Drossman Douglas A. New developments in the diagnosis and treatment of irritable bowel syndrome. Curr Gastroenterol Rep. 2002;4(5):427-434. Not about consequences of testing. [pmid: 12228046].
Lorini R, Scaramuzza A, Vitali L, et al. Clinical aspects of coeliac disease in children with insulin-dependent diabetes mellitus. J Pediatr Endocrinol Metab. 1996;9(Suppl 1):101-111. Not about consequences of testing. [pmid: 8887160].
Lorini R, Scotta M S, Cortona L, et al. Celiac disease and type I (insulin-dependent) diabetes mellitus in childhood: follow-up study. J Diabetes Complications. 1996;10(3):154-159. Not about consequences of testing. [pmid: 8807465].
Lubben James E, Chi Iris, Weiler Philip G. Differential health screening of the well elderly by gender and age: Appropriate care or bias?. J Appl Gerontol. 1989;8(3):335-354. Not about consequences of testing. [pmid: 10295407].
Ludvigsson J F, Falth-Magnusson K, Ludvigsson J. Tissue transglutaminase auto-antibodies in cord blood from children to become celiacs. Scand J Gastroenterol. 2001;36(12):1279-1283. Not about consequences of testing. [pmid: 11761017].
Lundberg A, Eriksson B O, Jansson G. Muscle abnormalities in coeliac disease: studies on gross motor development and muscle fibre composition, size and metabolic substrates. Eur J Pediatr. 1979;130(2):93-103. Not about consequences of testing. [pmid: 421695].
Luostarinen L K, Collin P O, Peraaho M J, et al. Coeliac disease in patients with cerebellar ataxia of unknown origin. Ann Med. 2001;33(6):445-449. Not about consequences of testing. [pmid: 11585106].
Luostarinen L, Dastidar P, Collin P, et al. Association between coeliac disease, epilepsy and brain atrophy. Eur Neurol. 2001;46(4):187-191. Not about consequences of testing. [pmid: 11721124].
Luostarinen L, Pirttila T, Collin P. Coeliac disease presenting with neurological disorders. Eur Neurol. 1999;42(3):132-135. Not about consequences of testing. [pmid: 10529537].
Mackey J, Treem W R, Worley G, et al. Frequency of celiac disease in individuals with Down syndrome in the United States. Clin Pediatr (Phila). 2001;40(5):249-252. Not about consequences of testing. [pmid: 11388673].
Mader R, Adawi M, Schonfeld S. Malabsorption in systemic lupus erythematosus. Clin Exp Rheumatol. 1997;15(6):659-661. Not about consequences of testing. [pmid: 9444423].
Magazzu G, Bottari M, Tuccari G, et al. Upper gastrointestinal endoscopy can be a reliable screening tool for celiac sprue in adults. J Clin Gastroenterol. 1994;19(3):255-257. Not about consequences of testing. [pmid: 7806840].
Magazzu G, Bottaro G, Cataldo F, et al. Increasing incidence of childhood celiac disease in Sicily: results of a multicenter study. Acta Paediatr. 1994;83(10):1065-1069. Not about consequences of testing. [pmid: 7841706].
Magazzu G, Jacono G, Di Pasquale G, et al. Reliability and usefulness of random fecal alpha 1-antitrypsin concentration: further simplification of the method. J Pediatr Gastroenterol Nutr. 1985;4(3):402-407. Not about consequences of testing. [pmid: 3874949].
Magliocca F M, Bonamico M, Petrozza V, et al. Usefulness of endoscopic small intestinal biopsies in children with coeliac disease. Ital J Anat Embryol. 2001;106(2 Suppl 1):329-335. Not about consequences of testing. [pmid: 11729974].
Mahadeva S, Wyatt J I, Howdle P D. Is a raised intraepithelial lymphocyte count with normal duodenal villous architecture clinically relevant?. Am J Clin Pathol. 2002;55(6):424-428. Not about consequences of testing.
Mahoney Diane F. One simple solution to hearing impairment. Geriatr Nurs (Minneap). 1987;8(5):242-245. Not about consequences of testing.
Maiuri L, Ciacci C, Vacca L, et al. IL-15 drives the specific migration of CD94+ and TCR-gammadelta+ intraepithelial lymphocytes in organ cultures of treated celiac patients. Am J Gastroenterol. 2001;96(1):150-156. Not about consequences of testing. [pmid: 11197245].
Maiuri L, Troncone R, Mayer M, et al. In vitro activities of A-gliadin-related synthetic peptides: damaging effect on the atrophic coeliac mucosa and activation of mucosal immune response in the treated coeliac mucosa. Scand J Gastroenterol. 1996;31(3):247-253. Not about consequences of testing. [pmid: 8833354].
Maki M, Aine L, Lipsanen V, et al. Dental enamel defects in first-degree relatives of coeliac disease patients. Lancet. 1991;337(8744):763-764. Not about consequences of testing. [pmid: 1672395].
Maki M, Hallstrom O, Huupponen T, et al. Increased prevalence of coeliac disease in diabetes. Arch Dis Child. 1984;59(8):739-742. Not about consequences of testing. [pmid: 6476871].
Maki M, Hallstrom O, Vesikari T, et al. Evaluation of a serum IgA-class reticulin antibody test for the detection of childhood celiac disease. Eur J Pediatr. 1984;105(6):901-905. Not about consequences of testing.
Maki M, Huupponen T, Holm K, et al. Seroconversion of reticulin autoantibodies predicts coeliac disease in insulin dependent diabetes mellitus. Gut. 1995;36(2):239-242. Not about consequences of testing. [pmid: 7883223]. [pmcid: 1382410].
Maki M, Lahdeaho M L, Hallstrom O, et al. Postpubertal gluten challenge in coeliac disease. Arch Dis Child. 1989;64(11):1604-1607. Not about consequences of testing. [pmid: 2604420].
Maki M, Sulkanen S, Collin P. Antibodies in relation to gluten intake. Dig Dis. 1998;16(6):330-332. Not about consequences of testing. [pmid: 10207216].
Maki Markku, Mustalahti Kirsi, Kokkonen Jorma, et al. Prevalence of Celiac disease among children in Finland. N Engl J Med. 2003;348(25):2517-2524. Not about consequences of testing. [pmid: 12815137].
Maldonado J E, Gregg J A, Green P A, et al. Chronic idiopathic intestinal pseudo-obstruction. Am J Med. 1970;49(2):203-212. Not about consequences of testing. [pmid: 5452942].
Mallas E, Terry J M, Asquith P, et al. Serum lysozyme in inflammatory bowel and coeliac disease. Am J Clin Pathol. 1976;29(7):598-600. Not about consequences of testing.
Malnick S D, Lurie Y, Beergabel M, et al. Celiac disease. Postgrad Med. 1997;101(6):239-244. Not about consequences of testing. [pmid: 9194877].
Mamon Joyce A, Shediac Mona C, Crosby Coral B, et al. Development and implementation of an intervention to increase cervical cancer screening in inner-city women. Int Q Community Health Educ. 1991;12(1):21-34. Not about consequences of testing. [pmid: 20840956].
Mandal A, Mayberry J. How common is celiac disease in South America?. Am J Gastroenterol. 2000;95(3):579-580. Not about consequences of testing. [pmid: 10710041].
Mantzaris G J, Tsirogianni A, Perivolioti E, et al. Sensitivity and specificity of serum IgA class endomysial antibody in the diagnosis of coeliac disease. Hell J Gastroenterol. 1996;8(4):308-311. Not about consequences of testing.
Mariani P, Viti M G, Montuori M, et al. The gluten-free diet: a nutritional risk factor for adolescents with celiac disease?. J Pediatr Gastroenterol Nutr. 1998;27(5):519-523. Not about consequences of testing. [pmid: 9822315].
Marien P, Molla A M, Eggermont E. Coeliac disease in childhood. Problems in differential diagnosis. Acta Gastroenterol Belg. 1986;49(4):387-392. Not about consequences of testing. [pmid: 3577607].
Marinello D, Rapa A, Osello R, et al. Celiac disease screening: exploring the iceberg with salivary antigliadin antibodies. J Pediatr Gastroenterol Nutr. 2001;32(2):227-228. Not about consequences of testing. [pmid: 11321405].
Marsh M N, Miller V. Studies of intestinal lymphoid tissue. VIII. Use of epithelial lymphocyte mitotic indices in differentiating untreated celiac sprue mucosa from other childhood enteropathies. J Pediatr Gastroenterol Nutr. 1985;4(6):931-935. Not about consequences of testing. [pmid: 4067781].
Marsh M N. Screening for latent gluten sensitivity: questions many, but answers few. Eur J Gastroenterol Hepatol. 1996;8(1):3-6. Unable to obtain article. [pmid: 8900901].
Marshall C M, Grunow J E. Emesis in infants as a consequence of feedings. Semin Pediatr Surg. 1995;4(3):147-151. Not about consequences of testing. [pmid: 7582884].
Martelossi S, Torre G, Zanatta M, et al. Dental enamel defects and screening for coeliac disease. Pediatr Med Chir. 1996;18(6):579-581. Not about consequences of testing. [pmid: 9127876].
Martelossi S, Zanatta E, Del Santo E, et al. Dental enamel defects and screening for coeliac disease. Acta Paediatr. 1996;412(Suppl):47-48. Not about consequences of testing.
Martinelli P, Troncone R, Paparo F, et al. Coeliac disease and unfavourable outcome of pregnancy. Gut. 2000;46(3):332-335. Not about consequences of testing. [pmid: 10673293]. [pmcid: 1727862].
Martini Silvia, Mengozzi Giulio, Aimo Giuseppe, et al. Comparative evaluation of serologic tests for celiac disease diagnosis and follow-up. Clin Chem. 2002;48(6 Pt 1):960-963. Not about consequences of testing. [pmid: 12029021].
Martucci S, Biagi F, Di Sabatino A, et al. Coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(Suppl 2):150-153. Not about consequences of testing. [pmid: 12408460].
Masala S, Annibale B, Fiori R, et al. DXA vs. QCT for subclinical celiac disease patients. Acta Diabetol Lat. 2003;40(Suppl 1):S174-S176. Not about consequences of testing.
Mascart-Lemone F, Lambrechts A. Serology of coeliac disease: early diagnosis and therapeutic impact. Acta Gastroenterol Belg. 1995;58(56):388-396. Not about consequences of testing. [pmid: 8775995].
Mascart-Lemone F, Van den, Broeck J, et al. Serological aspects of coeliac disease. Acta Gastroenterol Belg. 1992;55(2):200-208. Not about consequences of testing. [pmid: 1632137].
Mascart-Lemone F. Strategy for serological screening of celiac disease. Gastroenterol Int. 1998;11(3):144-148. Not about consequences of testing.
Matek Z, Jungvirth-Hegedus M, Kolacek S. Epidemiology of coeliac disease in children in one Croatian county: possible factors that could affect the incidence of coeliac disease and adherence to a gluten-free diet (Part II). Coll Antropol. 2000;24(2):397-404. Not about consequences of testing. [pmid: 11216408].
Mather K J, Meddings J B, Beck P L, et al. Prevalence of IgA-antiendomysial antibody in asymptomatic low bone mineral density. Am J Gastroenterol. 2001;96(1):120-125. Not about consequences of testing. [pmid: 11197240].
Mathus-Vliegen E M. Coeliac disease and lymphoma: current status. Neth J Med. 1996;49(5):212-220. Not about consequences of testing. [pmid: 8973099].
Matteucci E, Cinapri V, Quilici S, et al. Screening for coeliac disease in families of adults with Type 1 diabetes based on serological markers. Diabetes Nutr Metab. 2001;14(1):37-42. Not about consequences of testing. [pmid: 11345164].
Mauk Gary W, White Karl R. Giving children a sound beginning: The promise of universal newborn hearing screening. Volta Review. 1995;97(1):5-32. Not about consequences of testing.
Maurino E, Capizzano H, Niveloni S, et al. Value of endoscopic markers in celiac disease. Dig Dis Sci. 1993;38(11):2028-2033. Not about consequences of testing. [pmid: 8223077].
Mayer M, Greco L, Troncone R, et al. Compliance of adolescents with coeliac disease with a gluten free diet. Gut. 1991;32(8):881-885. Not about consequences of testing. [pmid: 1885070]. [pmcid: 1378956].
Mazure R M, Vazquez H, Gonzalez D, et al. Early changes of body composition in asymptomatic celiac disease patients. Am J Gastroenterol. 1996;91(4):726-730. Not about consequences of testing. [pmid: 8677938].
Mazzetti di, Pietralata Giorgetti G M, Gregori M, et al. Subclinical coeliac disease. Ital J Gastroenterol. 1992;24(6):352-354. Not about consequences of testing. [pmid: 1515663].
McBee J W. The sprue syndrome. Tex Med. 1966;62(12):54-56. Not about consequences of testing. [pmid: 5980424].
McCaul Kevin D, Reid Patricia A, Rathge Richard W, et al. Does concern about breast cancer inhibit or promote breast cancer screening?. Basic Appl Soc Psych. 1996;18(2):183-194. Not about consequences of testing.
McCrae W M, Eastwood M A, Martin M R, et al. Neglected coeliac disease. Lancet. 1975;1(7900):187-190. Not about consequences of testing. [pmid: 47419].
McElvaney N G, Duignan R, Fielding J F. Coeliac disease: clinical presentations, correlations of dietary compliance, symptomatic response and repeat biopsy findings. Ulster Med J. 1992;61(2):134-138. Not about consequences of testing. [pmid: 1481302].
McIntyre A S, Ng D P, Smith J A, et al. The endoscopic appearance of duodenal folds is predictive of untreated adult celiac disease. Gastrointest Endosc. 1992;38(2):148-151. Not about consequences of testing. [pmid: 1568611].
McMillan S A, Haughton D J, Biggart J D, et al. Predictive value for coeliac disease of antibodies to gliadin, endomysium, and jejunum in patients attending for jejunal biopsy. BMJ. 1991;303(6811):1163-1165. Not about consequences of testing. [pmid: 1747612]. [pmcid: 1671497].
McMillan S A, Johnston S D, Watson R G, et al. Dietary intake, smoking, and transient anti-gliadin antibodies. Scand J Gastroenterol. 1998;33(5):499-503. Not about consequences of testing. [pmid: 9648989].
McNeish A S, Harms H K, Rey J, et al. The diagnosis of coeliac disease. A commentary on the current practices of members of the European Society for Paediatric Gastroenterology and Nutrition (ESPGAN). Arch Dis Child. 1979;54(10):783-786. Not about consequences of testing. [pmid: 507902].
McNeish A S, Willoughby M L. Whole-blood folate as a screening test for coeliac disease in childhood. Lancet. 1969;1(7592):442-443. Not about consequences of testing. [pmid: 4179504].
McNeish A S. Diagnosis of coeliac disease in retrospect. Arch Dis Child. 1968;43(229):362-364. Not about consequences of testing. [pmid: 5666679].
McNicholl B, Egan-Mitchell B, Stevens F, et al. Mucosal recovery in treated childhood celiac disease (gluten-sensitive enteropathy). Eur J Pediatr. 1976;89(3):418-424. Not about consequences of testing.
McNicholl B. Childhood coeliac disease. J Ir Med Assoc. 1970;63(391):1-7. Not about consequences of testing. [pmid: 5411094].
McNicholl B. Coeliac disease: ecology, life history and management. Hum Nutr Appl Nutr. 1986;40(1):55-60. Not about consequences of testing. [pmid: 3528073].
McPhillips J. Understanding coeliac disease: symptoms and long-term risks. Br J Nurs. 2000;9(8):479-483. Not about consequences of testing. [pmid: 11143669].
Mearin M L, Polanco I, Strober W, et al. B-cell antigens recognized by maternal antisera in gluten-sensitive enteropathy. J Clin Nutr Gastroenterol. 1986;1(1):30-36. Not about consequences of testing.
Meijer Jos W R, Wahab Peter J, Mulder Chris J J. Small intestinal biopsies in celiac disease: duodenal or jejunal?. Virchows Arch. 2002;442(2):124-128. Not about consequences of testing. [pmid: 12596062].
Meloni G F, Dessole S, Vargiu N, et al. The prevalence of coeliac disease in infertility. Hum Reprod. 1999;14(11):2759-2761. Not about consequences of testing. [pmid: 10548618].
Meloni G F, Tomasi P A, Bertoncelli A, et al. Prevalence of silent celiac disease in patients with autoimmune thyroiditis from Northern Sardinia. J Endocrinol Invest. 2001;24(5):298-302. Not about consequences of testing. [pmid: 11407647].
Menendez-Corrada R. Current views on tropical sprue and a comparison to nontropical sprue. Med Clin North Am. 1968;52(6):1367-1385. Not about consequences of testing. [pmid: 4886058].
Menni S, Cavalli R, Prampolini R, et al. Dental enamel defects in children suffering from dermatitis herpetiformis and in their first degree relatives. Eur J Pediatr Dermatol. 1996;6(1):33-38. Not about consequences of testing.
Messmann H. Squamous cell cancer of the oesophagus. Baillieres Best Pract Res Clin Gastroenterol. 2001;15(2):249-265. Not about consequences of testing.
Metcalf J. Coeliac disease and primary biliary cirrhosis: a case for mutual screening. Gut. 1998;42(1):9-10. Not about consequences of testing. [pmid: 9505876].
Meyer D, Stavropolous S, Diamond B, et al. Osteoporosis in a north american adult population with celiac disease. Am J Gastroenterol. 2001;96(1):112-119. Not about consequences of testing. [pmid: 11197239].
Mic caron, Umek-Bradac caron, Dolins caron, et al. Ultrasonographic assessment of celiac disease in children: Comparison with antiendomysium antibodies and histology. Wien Klin Wochenschr Suppl. 2001;113(3):27-31. Not about consequences of testing.
Michaelsson G, Gerden B, Hagforsen E, et al. Psoriasis patients with antibodies to gliadin can be improved by a gluten-free diet. Br J Dermatol. 2000;142(1):44-51. Not about consequences of testing. [pmid: 10651693].
Michaelsson G, Gerden B, Ottosson M, et al. Patients with psoriasis often have increased serum levels of IgA antibodies to gliadin. Br J Dermatol. 1993;129(6):667-673. Not about consequences of testing. [pmid: 8286249].
Michaelsson G, Kraaz W, Gerden B, et al. Increased lymphocyte infiltration in duodenal mucosa from patients with psoriasis and serum IgA antibodies to gliadin. Br J Dermatol. 1995;133(6):896-904. Not about consequences of testing. [pmid: 8547041].
Michie S, Johnston M, Cockcroft A, et al. Methods and impact of health screening for hospital staff. Journal of Organizational Behavior. 1995;16(1):85-92. Not about consequences of testing.
Miller A, Paspaliaris W, Elliott P R, et al. Anti-transglutaminase antibodies and coeliac disease. Aust N Z J Med. 1999;29(2):239-242. Not about consequences of testing. [pmid: 10342024].
Mills P R, Horton P W, Watkinson G. The value of the 14C breath test in the assessment of fat absorption. Scand J Gastroenterol. 1979;14(8):914-920. Not about consequences of testing. [pmid: 531511].
Misra S, Ament M E. Diagnosis of coeliac sprue in 1994. Gastroenterology Clinics of North Am. 1995;24(1):133-143. Not about consequences of testing.
Mitchell C J, Field H P, Simpson F G, et al. Preliminary evaluation of a single-day tubeless test of pancreatic function. Br Med J (Clin Res Ed). 1981;282(6278):1751-1753. Not about consequences of testing. [pmid: 6786606].
Mohindra S, Yachha S K, Srivastava A, et al. Coeliac disease in Indian children: assessment of clinical, nutritional and pathologic characteristics. J Health Popul Nutr. 2001;19(3):204-208. Not about consequences of testing. [pmid: 11761775].
Molteni N, Bardella M T, Bianchi P A. Obstetric and gynecological problems in women with untreated celiac sprue. J Clin Gastroenterol. 1990;12(1):37-39. Not about consequences of testing. [pmid: 2303686].
Monteiro E, Menezes M L, Magalhaes Ramalho P. Anti-reticulin antibodies: a diagnostic and monitoring test for childhood coeliac disease. Scand J Gastroenterol. 1986;21(8):955-957. Not about consequences of testing. [pmid: 3535013].
Montgomery R D, Atiyeh M, Scales W R, et al. Intestinal absorption in Saudi Arabia: an evaluation of the one hour blood xylose test. Trans R Soc Trop Med Hyg. 1982;76(1):25-28. Not about consequences of testing. [pmid: 7080153].
Moodie S, Ciclitira P. Recent developments in celiac disease. Curr Opin Gastroenterol. 2002;18(2):182-186. Not about consequences of testing. [pmid: 17033284].
Mooradian A D, Morley J E, Levine A S, et al. Abnormal intestinal permeability to sugars in diabetes mellitus. Diabetologia. 1986;29(4):221-224. Not about consequences of testing. [pmid: 3519337].
Morris M A, Ciclitira P J. Coeliac disease. J R Coll Physicians Lond. 1997;31(6):614-618. Not about consequences of testing. [pmid: 9409492].
Mortimer P E, Stewart J S, Norman A P, et al. Follow-up study of coeliac disease. Br Med J. 1968;3(609):7-9. Not about consequences of testing. [pmid: 5661931]. [pmcid: 1989483].
Mottaleb A, Kapp F, Noguera E C, et al. The Lundh test in the diagnosis of pancreatic disease: a review of five years' experience. Gut. 1973;14(11):835-841. Not about consequences of testing. [pmid: 4761602]. [pmcid: 1412844].
Muench R, Ammann R. Fecal immunoreactive lipase: a new tubeless pancreatic function test. Scand J Gastroenterol. 1992;27(4):289-294. Not about consequences of testing. [pmid: 1589707].
Mugica F, Castiella A, Otazua P, et al. Prevalence of coeliac disease in unexplained chronic hypertransaminasemia. Revista Espanola De Enfermedades Digestivas - Organo Oficial De La Sociedad Espanola De Patologia Digestiva. 2001;93(11):707-714. Not about consequences of testing. [pmid: 11995370].
Mulder C J, van Bergeijk J D, Jansen T L, et al. Coeliac disease. Diagnostic and therapeutic pitfalls. Scand J Gastroenterol. 1993;200(Suppl):42-47. Review article.
Mulder C J, Wahab P J, Moshaver B, et al. Refractory coeliac disease: a window between coeliac disease and enteropathy associated T cell lymphoma. Scand J Gastroenterol. 2000;232(Suppl):32-37. Not about consequences of testing.
Mulder C J. Do we have to screen the general population for coeliac disease instead of only patients with so-called associated diseases?. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2000;32(9):780-781. Not about consequences of testing. [pmid: 11215558].
Mulder Chris J J, Hadithi Mohammed M, Rostami Kamran, et al. Coeliac disease--has the time come for routine mass screening? In 2002--2010--2020?. Rom J Gastroenterol. 2002;11(3):179-182. Not about consequences of testing. [pmid: 12368936].
Munck L K, Kjeldsen J, Philipsen E, et al. Incomplete remission with short-term prednisolone treatment in collagenous colitis: A randomized study. Scand J Gastroenterol. 2003;38(6):606-610. Not about consequences of testing. [pmid: 12825868].
Murphy M S, Sood M, Johnson T. Use of the lactose H2 breath test to monitor mucosal healing in coeliac disease. Acta Paediatr. 2002;91(2):141-144. Not about consequences of testing. [pmid: 11951999].
Murphy M S, Walker W A. Celiac disease. Pediatr Rev. 1991;12(11):325-330. Not about consequences of testing. [pmid: 2062743].
Murray J A, Van Dyke C, Plevak M F, et al. Trends in the identification and clinical features of celiac disease in a North American community, 1950-2001. Clin Gastroenterol Hepatol. 2003;1(1):19-27. Not about consequences of testing. [pmid: 15017513].
Murray J A. It's not time to put away the biopsy forceps. Am J Gastroenterol. 1999;94(4):869-871. Not about consequences of testing. [pmid: 10201447].
Murray J A. Serodiagnosis of celiac disease. Clin Lab Med. 1997;17(3):445-464. Not about consequences of testing. [pmid: 9316768].
Murray J A. The widening spectrum of celiac disease. Am J Clin Nutr. 1999;69(3):354-365. Not about consequences of testing. [pmid: 10195608].
Murray Michael, McMillan Carol. Health beliefs, locus of control, emotional control and women's cancer screening behaviour. Br J Clin Psychol. 1993;32(1):87-100. Not about consequences of testing. [pmid: 8467279].
Mustadjab I, Soeparto P, Karyadi. Floating test (Rossipal) for screening patients with fat malabsorption. Paediatr Indones. 1980;20(56):104-110. Not about consequences of testing. [pmid: 6252529].
Mustalahti K, Sulkanen S, Holopainen P, et al. Coeliac disease among healthy members of multiple case coeliac disease families. Scand J Gastroenterol. 2002;37(2):161-165. Not about consequences of testing. [pmid: 11843051].
Mustalahti Kirsi, Lohiniemi Susanna, Collin Pekka, et al. Gluten-free diet and quality of life in patients with screen-detected celiac disease. Eff Clin Pract. 2002;5(3):105-113. Not about consequences of testing. [pmid: 12088289].
Myhre A G, Aarsetoy H, Undlien D E, et al. High frequency of coeliac disease among patients with autoimmune adrenocortical failure. Scand J Gastroenterol. 2003;38(5):511-515. Not about consequences of testing. [pmid: 12795461].
Nathavitharana K A, Lloyd D R, Raafat F, et al. Urinary mannitol: lactulose excretion ratios and jejunal mucosal structure. Arch Dis Child. 1988;63(9):1054-1059. Not about consequences of testing. [pmid: 3140738].
Nehra V. New clinical issues in celiac disease. Gastroenterol Clin North Am. 1998;27(2):453-465. Not about consequences of testing. [pmid: 9650027].
Neilson Aileen R, Whynes David K. Determinants of persistent compliance with screening for colorectal cancer. Soc Sci Med. 1995;41(3):365-374. Not about consequences of testing. [pmid: 7481930].
Nelsen David A. Gluten-sensitive enteropathy (celiac disease): more common than you think. Am Fam Physician. 2002;66(12):2259-2266. Not about consequences of testing. [pmid: 12507163].
Neuberger J. PBC and the gut: the villi atrophy, the plot thickens. Gut. 1999;44(5):594-595. Not about consequences of testing. [pmid: 10485854]. [pmcid: 1727492].
Neuhausen Susan L, Feolo Mike, Camp Nicola J, et al. Genome-wide linkage analysis for celiac disease in North American families. Am J Med Genet. 2002;111(1):1-9. Not about consequences of testing. [pmid: 12124726].
Newcomer A D, Hofmann A F, DiMagno E P, et al. Triolein breath test: a sensitive and specific test for fat malabsorption. Gastroenterology. 1979;76(1):6-13. Not about consequences of testing. [pmid: 758149].
Nielsen O H, Jacobsen O, Pedersen E R. Non-tropical sprue. Malignant diseases and mortality rate. Scand J Gastroenterol. 1985;20(1):13-18. Not about consequences of testing. [pmid: 3992161].
Nieminen U, Kahri A, Savilahti E, et al. Duodenal disaccharidase activities in the follow-up of villous atrophy in coeliac disease. Scand J Gastroenterol. 2001;36(5):507-510. Not about consequences of testing. [pmid: 11346204].
Nieto A, Blanco Quiros A, Arranz E, et al. Study of HLA-DQA1 alleles in celiac children. Journal of Investigational Allergology & Clinical Immunology - Official Organ of the International Association of Asthmology (Interasma) and Sociedad Latinoamericana De Alergia E Inmunologia. 1995;5(4):209-215. Not about consequences of testing. [pmid: 8705011].
Nilsen E M, Johansen F E, Jahnsen F L, et al. Cytokine profiles of cultured microvascular endothelial cells from the human intestine. Gut. 1998;42(5):635-642. Not about consequences of testing. [pmid: 9659156]. [pmcid: 1727090].
Niveloni S, Fiorini A, Dezi R, et al. Usefulness of videoduodenoscopy and vital dye staining as indicators of mucosal atrophy of celiac disease: assessment of interobserver agreement. Gastrointest Endosc. 1998;47(3):223-229. Not about consequences of testing. [pmid: 9580349].
Niveloni S, Pedreira S, Sugai E, et al. The natural history of gluten sensitivity: report of two new celiac disease patients resulting from a long-term follow-up of nonatrophic, first-degree relatives. Am J Gastroenterol. 2000;95(2):463-468. Not about consequences of testing. [pmid: 10685751].
Norman Paul, Fitter Mike. Intention to attend a health screening appointment: Some implications for general practice. Couns Psychol. 1989;2(3):261-272. Not about consequences of testing.
Norman Paul, Fitter Mike. Predicting attendance at health screening: Organizational factors and patients' health beliefs. Couns Psychol. 1991;4(23):143-155. Not about consequences of testing.
Norman Paul. Applying the health belief model to the prediction of attendance at health checks in general practice. Br J Clin Psychol. 1995;34(3):461-470. Not about consequences of testing. [pmid: 8845784].
Norman Paul. Social learning theory and the prediction of attendance at screening. Psychol Health. 1991;5(3):231-239. Not about consequences of testing.
Nosari I, Casati A, Mora C, et al. The use of IgA-antiendomysial antibody test for screening coeliac disease in insulin-dependent diabetes mellitus. Diabetes Nutr Metab Clin Exp. 1996;9(5):267-272. Not about consequences of testing.
Not T, Citta A, Lucchesi A, et al. Anti-endomysium antibody on human umbilical cord vein tissue: an inexpensive and sensitive diagnostic tool for the screening of coeliac disease. Eur J Pediatr. 1997;156(8):616-618. Not about consequences of testing. [pmid: 9266192].
Not T, Horvath K, Hill I D, et al. Celiac disease risk in the USA: high prevalence of antiendomysium antibodies in healthy blood donors. Scand J Gastroenterol. 1998;33(5):494-498. Not about consequences of testing. [pmid: 9648988].
Not T, Tommasini A, Tonini G, et al. Undiagnosed coeliac disease and risk of autoimmune disorders in subjects with Type I diabetes mellitus. Diabetologia. 2001;44(2):151-155. Not about consequences of testing. [pmid: 11270670].
Not T, Ventura A, Peticarari S, et al. A new, rapid, noninvasive screening test for celiac disease. Eur J Pediatr. 1993;123(3):425-427. Not about consequences of testing.
Not Tarcisio, Faleschini Elena, Tommasini Alberto, et al. Celiac disease in patients with sporadic and inherited cardiomyopathies and in their relatives. Eur Heart J. 2003;24(15):1455-1461. Not about consequences of testing. [pmid: 12909075].
Nuti R, Martini G, Valenti R, et al. Prevalence of undiagnosed coeliac syndrome in osteoporotic women. J Intern Med. 2001;250(4):361-366. Not about consequences of testing. [pmid: 11576323].
Nyren O, Adami H O, Gustavsson S, et al. The “epigastric distress syndrome”. A possible disease entity identified by history and endoscopy in patients with nonulcer dyspepsia. J Clin Gastroenterol. 1987;9(3):303-309. Not about consequences of testing. [pmid: 3655274].
Oberhuber G, Granditsch G, Vogelsang H. The histopathology of coeliac disease: time for a standardized report scheme for pathologists. Eur J Gastroenterol Hepatol. 1999;11(10):1185-1194. Not about consequences of testing. [pmid: 10524652].
O'Brien C J, Saverymuttu S, Hodgson H J F, et al. Coeliac disease, adenocarcinoma of jejunum and in situ squamous carcinoma of oesophagus. J Clin Pathol. 1983;36(1):62-67. Not about consequences of testing. [pmid: 6822678]. [pmcid: 498106].
O'Farrelly C, Feighery C, O'Briain D S, et al. Humoral response to wheat protein in patients with coeliac disease and enteropathy associated T cell lymphoma. Br Med J (Clin Res Ed). 1986;293(6552):908-910. Not about consequences of testing. [pmid: 3094712].
O'Farrelly C, Kelly J, Hekkens W, et al. Alpha gliadin antibody levels: a serological test for coeliac disease. Br Med J (Clin Res Ed). 1983;286(6383):2007-2010. Not about consequences of testing. [pmid: 6409205].
Olden Kevin W. Diagnosis of irritable bowel syndrome. Gastroenterology. 2002;122(6):1701-1714. Not about consequences of testing. [pmid: 12454866].
O'Leary C, Walsh C H, Wieneke P, et al. Coeliac disease and autoimmune Addison's disease: a clinical pitfall. QJM. 2002;95(2):79-82. Not about consequences of testing. [pmid: 11861954].
O'Leary Clare, Quigley Eamonn M M. Small bowel bacterial overgrowth, celiac disease, and IBS: what are the real associations?. Am J Gastroenterol. 2003;98(4):720-722. Not about consequences of testing. [pmid: 12738446].
Olsen W A. A practical approach to diagnosis of disorders of intestinal absorption. N Engl J Med. 1971;285(24):1358-1361. Not about consequences of testing. [pmid: 4941276].
Onstad G R, Zieve L. Carotene absorption. A screening test for steatorrhea. JAMA. 1972;221(7):677-679. Not about consequences of testing. [pmid: 5068266].
Osman A A, Gunnel T, Dietl A, et al. B cell epitopes of gliadin. Clin Exp Immunol. 2000;121(2):248-254. Not about consequences of testing. [pmid: 10931138]. [pmcid: 1905697].
Osman A A, Uhlig H H, Valdes I, et al. A monoclonal antibody that recognizes a potential coeliac-toxic repetitive pentapeptide epitope in gliadins. Eur J Gastroenterol Hepatol. 2001;13(10):1189-1193. Not about consequences of testing. [pmid: 11711775].
Osman A A, Uhlig H, Thamm B, et al. Use of the phage display technique for detection of epitopes recognized by polyclonal rabbit gliadin antibodies. FEBS Lett. 1998;433(12):103-107. Not about consequences of testing. [pmid: 9738942].
Oxentenko Amy S, Grisolano Scott W, Murray Joseph A, et al. The insensitivity of endoscopic markers in celiac disease. Am J Gastroenterol. 2002;97(4):933-938. Not about consequences of testing. [pmid: 12003429].
Pacht A, Sinai N, Hornstein L, et al. The diagnostic reliability of anti-endomysial antibody in celiac disease: the north Israel experience. Isr J Med Sci. 1995;31(4):218-220. Not about consequences of testing. [pmid: 7721558].
Packer S, Rowlatt R J, Harries J T. Proceedings: Reappraisal of a past diagnosis of “coeliac disease”. Arch Dis Child. 1974;49(10):819. Not about consequences of testing. [pmid: 4429369].
Paerregaard A, Vilien M, Krasilnikoff P A, et al. Supposed coeliac disease during childhood and its presentation 14–38 years later. Scand J Gastroenterol. 1988;23(1):65-70. Not about consequences of testing. [pmid: 3344399].
Page S R, Lloyd C A, Hill P G, et al. The prevalence of coeliac disease in adult diabetes mellitus. QJM. 1994;87(10):631-637. Not about consequences of testing. [pmid: 7987659].
Paimela L, Kurki P, Leirisalo-Repo M, et al. Gliadin immune reactivity in patients with rheumatoid arthritis. Clin Exp Rheumatol. 1995;13(5):603-607. Not about consequences of testing. [pmid: 8575138].
Palosuo K, Alenius H, Varjonen E, et al. A novel wheat gliadin as a cause of exercise-induced anaphylaxis. J Allergy Clin Immunol. 1999;103(5 Pt 1):912-917. Not about consequences of testing. [pmid: 10329828].
Papadatou B, Crino A, Giannotti A, et al. Antiendomysial and antigliadin antibodies in patients with Down syndrome. Dev Brain Dysfunct. 1996;9(23):129-132. Not about consequences of testing.
Pare P, Douville P, Caron D, et al. Adult celiac sprue: changes in the pattern of clinical recognition. J Clin Gastroenterol. 1988;10(4):395-400. Not about consequences of testing. [pmid: 3418086].
Parker S L, Sussman G L, Krondl M. Dietary aspects of adverse reactions to foods in adults. Cmaj - Canadian Medical Association Journal = Journal De L'association Medicale Canadienne. 1988;139(8):711-718. Not about consequences of testing.
Parnell N D, Ciclitira P J. Review article: coeliac disease and its management. Aliment Pharmacol Ther. 1999;13(1):1-13. Not about consequences of testing. [pmid: 10383530].
Parnell N, Ciclitira P J. Celiac disease. Curr Opin Gastroenterol. 1999;15(2):120-124. Not about consequences of testing. [pmid: 17023931].
Partanen J, Milner C, Campbell R D, et al. HLA-linked heat-shock protein 70 (HSP70-2) gene polymorphism and celiac disease. Tissue Antigens. 1993;41(1):15-19. Not about consequences of testing. [pmid: 8096093].
Patinen P, Bjorksten F, Malmstrom M, et al. Salivary and serum IgA antigliadin antibodies in dermatitis herpetiformis. Eur J Oral Sci. 1995;103(5):280-284. Not about consequences of testing. [pmid: 8521118].
Patterson R N, Johnston S D. Iron deficiency anaemia: are the British Society of Gastroenterology guidelines being adhered to?. Postgrad Med J. 2003;79(930):226-228. Not about consequences of testing. [pmid: 12743344].
Patwari A K, Anand V K, Kapur Gaurav, et al. Clinical and nutritional profile of children with celiac disease. Indian Pediatr. 2003;40(4):337-342. Not about consequences of testing. [pmid: 12736407].
Pearce Allum B, Sinclair David, Duncan Hamish D, et al. Use of the anti-endomysial antibody test to diagnose coeliac disease in clinical practice. Clin Lab. 2002;48(56):319-325. Not about consequences of testing. [pmid: 12071583].
Pecsi G. Genetic associations and immunopathogenesis of coeliac disease. Acta Physiol Hung. 2000;87(4):339-353. Not about consequences of testing. [pmid: 11732888].
Pellecchia M T, Ambrosio G, Salvatore E, et al. Possible gluten sensitivity in multiple system atrophy. Neurology. 2002;59(7):1114-1115. Not about consequences of testing. [pmid: 12370481].
Pellecchia M T, Scala R, Filla A, et al. Idiopathic cerebellar ataxia associated with celiac disease: lack of distinctive neurological features. J Neurol Neurosurg Psychiatry. 1999;66(1):32-35. Not about consequences of testing. [pmid: 9886447].
Pelli M A, Capodicasa E, De Angelis V, et al. Sorbitol Hinf 2-breath test in celiac disease. Importance of early positivity. Gastroenterol Int. 1998;11(2):65-68. Not about consequences of testing.
Pena A S, Garrote J A, Crusius J B. Advances in the immunogenetics of coeliac disease. Clues for understanding the pathogenesis and disease heterogeneity. Scand J Gastroenterol. 1998;255(Suppl):56-58. Not about consequences of testing.
Pena A S, Wijmenga C. Genetic factors underlying gluten-sensitive enteropathy. Curr Allergy Asthma Rep. 2001;1(6):526-533. Not about consequences of testing. [pmid: 11892082].
Pengiran Tengah D S N A, Wills A J, Holmes G K T. Neurological complications of coeliac disease. Postgrad Med J. 2002;78(921):393-398. Not about consequences of testing. [pmid: 12151653].
Peracchi Maddalena, Trovato Cristina, Longhi Massimo, et al. Tissue transglutaminase antibodies in patients with end-stage heart failure. Am J Gastroenterol. 2002;97(11):2850-2854. Not about consequences of testing. [pmid: 12425559].
Perera D R, Weinstein W M, Rubin C E. Symposium on pathology of the gastrointestinal tract-Part II. Small intestinal biopsy. Hum Pathol. 1975;6(2):157-217. Not about consequences of testing. [pmid: 50260].
Perri F, Andriulli A. “Mixed” triglyceride breath test: methodological problems and clinical applications. Rev Med Univ Navarra. 1998;42(2):99-103. Not about consequences of testing. [pmid: 10420946].
Perticarari S, Presani G, Trevisan M, et al. Serum IgA and IgG antibodies to alpha-gliadin: comparison between two ELISA methods. Ric Clin Lab. 1987;17(4):323-329. Not about consequences of testing. [pmid: 3438667].
Petaros P, Martelossi S, Tommasini A, et al. Prevalence of autoimmune disorders in relatives of patients with celiac disease. Dig Dis Sci. 2002;47(7):1427-1431. Not about consequences of testing. [pmid: 12141796].
Peters Ulrike, Askling Johan, Gridley Gloria, et al. Causes of death in patients with celiac disease in a population-based Swedish cohort. Arch Intern Med. 2003;163(13):1566-1572. Not about consequences of testing. [pmid: 12860579].
Petersen J, Drasche A, Raithel M, et al. Analysis of genetic polymorphisms of enzymes involved in histamine metabolism. Inflamm Res. 2003;52(Suppl 1):S69-S70. Not about consequences of testing. [pmid: 12755417].
Pham T H, Barr G D. Coeliac disease in adults. Presentation and management. Aust Fam Physician. 1996;25(1):62-65. Not about consequences of testing. [pmid: 8607777].
Piattella L, Zamponi N, Cardinali C, et al. Endocranial calcifications, infantile celiac disease, and epilepsy. Child's Nervous System - Chns - Official Journal of the International Society for Pediatric Neurosurgery. 1993;9(3):172-175. Not about consequences of testing. [pmid: 8374923].
Picarelli A, di Tola M, Sabbatella L, et al. Identification of a new coeliac disease subgroup: antiendomysial and anti-transglutaminase antibodies of IgG class in the absence of selective IgA deficiency. J Intern Med. 2001;249(2):181-188. Not about consequences of testing. [pmid: 11240848].
Picarelli A, Sabbatella L, di Tola M, et al. Celiac disease diagnosis in misdiagnosed children. Pediatr Res. 2000;48(5):590-592. Not about consequences of testing. [pmid: 11044476].
Picarelli A, Sabbatella L, di Tola M, et al. Forty-eight hours of biopsy culture improve the sensitivity of the in vitro gliadin challenge in the diagnosis of celiac disease. Clin Chem. 2001;47(10):1841-1843. Not about consequences of testing. [pmid: 11568096].
Picarelli A, Triglione P, Mariani P, et al. Use of a threshold serum level of anti-gliadin antibodies improves diagnostic efficiency of the test in adult coeliac disease but is unreliable as a screening test. Ital J Gastroenterol. 1996;28(2):70-75. Not about consequences of testing. [pmid: 8781997].
Picarelli Antonio, Sabbatella Luigi, Di Tola, et al. Antiendomysial antibody detection in fecal supernatants: in vivo proof that small bowel mucosa is the site of antiendomysial antibody production. Am J Gastroenterol. 2002;97(1):95-98. Not about consequences of testing. [pmid: 11808976].
Pittschieler K, Gentili L, Niederhofer H. Onset of coeliac disease: A prospective longitudinal study. Acta Paediatr. 2003;92(10):1149-1152. Not about consequences of testing. [pmid: 14632329].
Pittschieler K, Ladinser B. Coeliac disease: screened by a new strategy. Acta Paediatr. 1996;412(Suppl):42-45. Not about consequences of testing.
Polvi A, Arranz E, Fernandez-Arquero M, et al. HLA-DQ2-negative celiac disease in Finland and Spain. Hum Immunol. 1998;59(3):169-175. Not about consequences of testing. [pmid: 9548076].
Polvi A, Garden O A, Elwood C M, et al. Canine major histocompatibility complex genes DQA and DQB in Irish setter dogs. Tissue Antigens. 1997;49(3 Pt 1):236-243. Not about consequences of testing. [pmid: 9098930].
Popat S, Hearle N, Bevan S, et al. Mutational analysis of CD28 in coeliac disease. Scand J Gastroenterol. 2002;37(5):536-539. Not about consequences of testing. [pmid: 12059054].
Popat S, Hearle N, Wixey J, et al. Analysis of the CTLA4 gene in Swedish coeliac disease patients. Scand J Gastroenterol. 2002;37(1):28-31. Not about consequences of testing. [pmid: 11843030].
Popat S, Hogberg L, McGuire S, et al. Germline mutations in TGM2 do not contribute to coeliac disease susceptibility in the Swedish population. Eur J Gastroenterol Hepatol. 2001;13(12):1477-1479. Not about consequences of testing. [pmid: 11742196].
Popper Stephen E, Morris Charles E, Briggs Jeffrey. Human subject screening: A dynamic process. Aviat Space Environ Med. 1997;68(10):939-942. Not about consequences of testing. [pmid: 9327121].
Pozler O, Parizek J, Chylkova V, et al. Immunological aspects of diagnosis of celiac sprue in children. Sb Ved Pr Lek Fak Karlovy Univerzity Hradci Kralove. 1989;32(2):169-233. Not about consequences of testing. [pmid: 2604776].
Prasad S, Thomas P, Nicholas D S, et al. Adult endomysial antibody-negative coeliac disease and cigarette smoking. Eur J Gastroenterol Hepatol. 2001;13(6):667-671. Not about consequences of testing. [pmid: 11434592].
Pratesi R, Gandolfi L, Garcia S G, et al. Prevalence of coeliac disease: Unexplained age-related variation in the same population. Scand J Gastroenterol. 2003;38(7):747-750. Not about consequences of testing. [pmid: 12889561].
Pratesi R, Modelli I C, Martins R C, et al. Celiac disease and epilepsy: Favorable outcome in a child with difficult to control seizures. Acta Neurol Scand. 2003;108(4):290-293. Not about consequences of testing. [pmid: 12956865].
Pratesi Riccardo, Gandolfi Lenora, Martins Rita C, et al. Is the prevalence of celiac disease increased among epileptic patients?. Arq Neuropsiquiatr. 2003;61(2b):330-334. Not about consequences of testing. [pmid: 12894262].
Presani G, Perticarari S, Mangiarotti M A. Flow cytometric detection of anti-gliadin antibodies. J Immunol Methods. 1989;119(2):197-202. Not about consequences of testing. [pmid: 2656868].
Pringle E M, Young W F, Mortimer P E, et al. Coeliac syndrome. Proc R Soc Med. 1968;61(8):775-776. Not about consequences of testing. [pmid: 5673402].
Pruessner H T. Detecting celiac disease in your patients. Am Fam Physician 1998;57(5):1023–34, 1039. Not about consequences of testing
Pynnonen P, Isometsa E, Aalberg V, et al. Is coeliac disease prevalent among adolescent psychiatric patients?. Acta Paediatr. 2002;91(6):657-659. Not about consequences of testing. [pmid: 12162597].
Quaglino D, Corazza G R. Anaemias and other haematological changes due to disease of the alimentary tract. Recenti Prog Med. 1993;84(9):624-633. Not about consequences of testing. [pmid: 8210628].
Quisel Anna, Gill James M, Westerberg Dyanne. Guideline for diagnosis of celiac disease. Del Med J. 2002;74(5):229-241. Not about consequences of testing. [pmid: 12063834].
Ralston S H, Willocks L, Pitkeathly D A, et al. High prevalence of unrecognized osteomalacia in hospital patients with rheumatoid arthritis. Br J Rheumatol. 1988;27(3):202-205. Not about consequences of testing. [pmid: 3378124].
Rampton D S, Kasidas G P, Rose G A, et al. Oxalate loading test. A screening test for steatorrhoea. Gut. 1979;20(5):A456. Not about consequences of testing. [pmid: 527884].
Rampton D S, McCullough A D, Sabbat J S, et al. Screening for steatorrhoea with an oxalate loading test. Br Med J (Clin Res Ed). 1984;288(6428):1419. Not about consequences of testing. [pmid: 6426582].
Ransford Rupert A J, Hayes Mark, Palmer Martin, et al. A controlled, prospective screening study of celiac disease presenting as iron deficiency anemia. J Clin Gastroenterol. 2002;35(3):228-233. Not about consequences of testing. [pmid: 12192198].
Rasanen L, Lehto M, Turjanmaa K, et al. Allergy to ingested cereals in atopic children. Allergy. 1994;49(10):871-876. Not about consequences of testing. [pmid: 7535982].
Rasmusson C G, Eriksson M A. Celiac disease and mineralisation disturbances of permanent teeth. International Journal of Paediatric Dentistry / the British Paedodontic Society and the International Association of Dentistry for Children. 2001;11(3):179-183. Not about consequences of testing. [pmid: 11484467].
Rastogi A, Malhotra V, Uppal B, et al. Aetiology of chronic diarrhoea in tropical children. Trop Gastroenterol. 1999;20(1):45-49. Not about consequences of testing. [pmid: 10464450].
Rautonen J, Rautonen N, Savilahti E. Antibodies to gliadin in children with coeliac disease. Acta Paediatr Scand. 1991;80(12):1200-1206. Not about consequences of testing. [pmid: 1785292].
Ravaglia Giovanni, Forti Paola, Maioli Fabiola, et al. Increased prevalence of coeliac disease in autoimmune thyroiditis is restricted to aged patients. Exp Gerontol. 2003;38(5):589-595. Not about consequences of testing. [pmid: 12742537].
Ravelli A M, Tobanelli P, Minelli L, et al. Endoscopic features of celiac disease in children. Gastrointest Endosc. 2001;54(6):736-742. Not about consequences of testing. [pmid: 11726850].
Read M, O'Halloran E T, O'sullivan C. Coeliac disease in adolescents/young adults: difficulties in monitoring. Br J Biomed Sci. 2000;57(3):217-221. Not about consequences of testing. [pmid: 11050774].
Reeves G E, Burns C, Hall S T, et al. The measurement of IgA and IgG transglutaminase antibodies in celiac disease: a comparison with current diagnostic methods. Pathology. 2000;32(3):181-185. Not about consequences of testing. [pmid: 10968391].
Rensch M J, Merenich J A, Lieberman M, et al. Gluten-sensitive enteropathy in patients with insulin-dependent diabetes mellitus. Ann Intern Med. 1996;124(6):564-567. Not about consequences of testing. [pmid: 8597319].
Ribes C, Pena A S, Pereda A, et al. IGA gliadin antibodies, a useful screening test for coeliac disease in family members of children with coeliac disease. J Clin Nutr Gastroenterol. 1991;6(4):196-202. Not about consequences of testing.
Ribes-Koninckx C, Alfonso P, Ortigosa L, et al. A beta-turn rich oats peptide as an antigen in an ELISA method for the screening of coeliac disease in a paediatric population. Eur J Clin Invest. 2000;30(8):702-708. Not about consequences of testing. [pmid: 10964162].
Riccabona M, Rossipal E. Sonographic findings in celiac disease. J Pediatr Gastroenterol Nutr. 1993;17(2):198-200. Not about consequences of testing. [pmid: 8229548].
Rich E J, Christie D L. Anti-gliadin antibody panel and xylose absorption test in screening for celiac disease. J Pediatr Gastroenterol Nutr. 1990;10(2):174-178. Not about consequences of testing. [pmid: 2182821].
Riestra S, Fernandez E, Rodrigo L, et al. Prevalence of Coeliac disease in the general population of northern Spain. Strategies of serologic screening. Scand J Gastroenterol. 2000;35(4):398-402. Not about consequences of testing. [pmid: 10831263].
Robert M E, Ament M E, Weinstein W M. The histologic spectrum and clinical outcome of refractory and unclassified sprue. Am J Surg Pathol. 2000;24(5):676-687. Not about consequences of testing. [pmid: 10800986].
Roberts I M, Poturich C, Wald A. Utility of fecal fat concentrations as screening test in pancreatic insufficiency. Dig Dis Sci. 1986;31(10):1021-1024. Not about consequences of testing. [pmid: 3757718].
Roberts R K, Campbell C B, Bryant S J, et al. Xylose-1-14C absorption test: the use of urine, serum and breath analysis, and comparison with a colorimetric assay. Aust N Z J Med. 1976;6(6):532-536. Not about consequences of testing. [pmid: 1071535].
Robins Robert S, Post Jerrold M. Choosing a healthy president. Political Psychology. 1995;16(4):841-860. Not about consequences of testing.
Robinson T J, Nelson S D, Haire M. Jejunal villous changes associated with farmer's lung. Postgrad Med J. 1981;57(673):697-701. Not about consequences of testing. [pmid: 7339601].
Robinson T J. Coeliac disease with farmers' lung. Br Med J. 1976;1(6012):745-746. Not about consequences of testing. [pmid: 974637]. [pmcid: 1639169].
Rogers A I. Steatorrhea. Postgrad Med. 1971;50(6):123-129. Not about consequences of testing. [pmid: 5128036].
Roizen N J. Down syndrome: Progress in research. Ment Retard Dev Disabil Res Rev. 2001;7(1):38-44. Not about consequences of testing. [pmid: 11241881].
Roizen Nancy J, Patterson David. Down Syndrome. Lancet. 2003;361(9365):1281-1289. Not about consequences of testing. [pmid: 14511944].
Roldan M B, Barrio R, Roy G, et al. Diagnostic value of serological markers for celiac disease in diabetic children and adolescents. J Pediatr Endocrinol Metab. 1998;11(6):751-756. Not about consequences of testing. [pmid: 9829231].
Rolles C J, Kendall M J. One hour blood D-xylose as a screening test for malabsorption in infants and young children. Arch Dis Child. 1972;47(254):673. Not about consequences of testing. [pmid: 5046789].
Rolles C J, Nutter S, Kendall M J, et al. One-hour blood-xylose screening-test for coeliac disease in infants and young children. Lancet. 1973;2(7837):1043-1045. Not about consequences of testing. [pmid: 4127308].
Rona R J, Tanner J M. Aetiology of idiopathic growth hormone deficiency in England and Wales. Arch Dis Child. 1977;52(3):197-208. Not about consequences of testing. [pmid: 848998].
Rosa Utiyama S R, Silva Kotze L M, Nisihara R M, et al. Spectrum of autoantibodies in celiac patients and relatives. Dig Dis Sci. 2001;46(12):2624-2630. Not about consequences of testing. [pmid: 11768251].
Rosenman Kenneth D, Gardiner Joseph, Swanson G, et al. Use of skin-cancer prevention strategies among farmers and their spouses. Am J Prev Med. 1995;11(5):342-347. Not about consequences of testing. [pmid: 8573366].
Rosenthal E, Golan D T, Benderly A. Immunofluorescent antigluten antibody test. Titer and profile of gluten antibodies in celiac disease. Am J Dis Child. 1984;138(7):659-662. Not about consequences of testing. [pmid: 6375347].
Rossipal E, Mlekusch W. Steatorrhea, a simple and rapid method of diagnosis. Eur J Pediatr. 1976;122(4):297-302. Not about consequences of testing. [pmid: 939233].
Rostami K, Kerckhaert J P, Tiemessen R, et al. The relationship between anti-endomysium antibodies and villous atrophy in coeliac disease using both monkey and human substrate. Eur J Gastroenterol Hepatol. 1999;11(4):439-442. Not about consequences of testing. [pmid: 10321762].
Rostami K, Kerckhaert J, Tiemessen R, et al. Sensitivity of antiendomysium and antigliadin antibodies in untreated celiac disease: disappointing in clinical practice. Am J Gastroenterol. 1999;94(4):888-894. Not about consequences of testing. [pmid: 10201452].
Rostami K, Kerckhaert J, von Blomberg B M, et al. SAT and serology in adult coeliacs, seronegative coeliac disease seems a reality. Neth J Med. 1998;53(1):15-19. Not about consequences of testing. [pmid: 9718937].
Rostami K, Mulder C J J, Stapell S, et al. Autoantibodies and histogenesis of celiac disease. Rom J Gastroenterol. 2003;12(2):101-106. Not about consequences of testing. [pmid: 12853995].
Rostami K, Mulder C J, van Overbeek F M, et al. Should relatives of coeliacs with mild clinical complaints undergo a small-bowel biopsy despite negative serology?. Eur J Gastroenterol Hepatol. 2000;12(1):51-55. Not about consequences of testing. [pmid: 10656210].
Rostami K, Mulder C J, Werre J M, et al. High prevalence of celiac disease in apparently healthy blood donors suggests a high prevalence of undiagnosed celiac disease in the Dutch population. Scand J Gastroenterol. 1999;34(3):276-279. Not about consequences of testing. [pmid: 10232872].
Rostami K, Steegers E A, Wong W Y, et al. Coeliac disease and reproductive disorders: a neglected association. Eur J Obstet Gynecol Reprod Biol. 2001;96(2):146-149. Not about consequences of testing. [pmid: 11384797].
Rubin C E, Brandborg L L, Phelps P C et al. Studies of celiac disease. I. The apparent identical and specific nature of the duodenal and proximal jejunal lesion in celiac disease and idiopathic sprue. Gastroenterology 1968;54(4):Suppl:800–802. Not about consequences of testing
Rubin C E, Eidelman S, Weinstein W M. Sprue by any other name. Gastroenterology. 1970;58(3):409-413. Not about consequences of testing. [pmid: 5437995].
Rude R K, Olerich M. Magnesium deficiency: possible role in osteoporosis associated with gluten-sensitive enteropathy. Osteoporosis International - a Journal Established as Result of Cooperation Between the European Foundation for Osteoporosis and the National Osteoporosis Foundation of the Usa. 1996;6(6):453-461. Not about consequences of testing. [pmid: 9116391].
Rujner J, Brett-Chrusciel J, Piontek E, et al. Negative results for serum antiendomysial antibodies do not exclude late developing jejunal mucosal atrophy - A case of latent coeliac disease in a 12-year old boy with type 1 diabetes mellitus. Pediatr Wspolczesna. 2002;4(3):331-333. Not about consequences of testing.
Rujner J, Socha J, Barra E, et al. Serum and salivary antigliadin antibodies and serum IgA anti-endomysium antibodies as a screening test for coeliac disease. Acta Paediatr. 1996;85(7):814-817. Not about consequences of testing. [pmid: 8819547].
Rumbo M, Chirdo F G, Ben R, et al. Evaluation of coeliac disease serological markers in Down syndrome patients. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(2):116-121. Not about consequences of testing. [pmid: 11926554].
Ruokonen J. Reactions in the cytotoxic leucocyte test. Allergol Immunopathol (Madr). 1981;9(4):281-288. Not about consequences of testing. [pmid: 7304370].
Ruskone-Fourmestraux A, Rambaud J C. Gastrointestinal lymphoma: prevention and treatment of early lesions. Baillieres Best Pract Res Clin Gastroenterol. 2001;15(2):337-354. Not about consequences of testing.
Russo P A, Chartrand L J, Seidman E. Comparative analysis of serologic screening tests for the initial diagnosis of celiac disease. Pediatrics. 1999;104(1 Pt 1):75-78. Not about consequences of testing. [pmid: 10390263].
Ryan J. Coeliac disease. Update 2000. Aust Fam Physician. 2000;29(9):835-838. Not about consequences of testing. [pmid: 11008385].
Sacchetti L, Calcagno G, Ferrajolo A, et al. Discrimination between celiac and other gastrointestinal disorders in childhood by rapid human lymphocyte antigen typing. Clin Chem. 1998;44(8 Pt 1):1755-1757. Not about consequences of testing. [pmid: 9702970].
Sacchetti L, Ferrajolo A, Salerno G, et al. Diagnostic value of various serum antibodies detected by diverse methods in childhood celiac disease. Clin Chem. 1996;42(11):1838-1842. Not about consequences of testing. [pmid: 8906085].
Salmaso C, Ocmant A, Pesce G, et al. Comparison of ELISA for tissue transglutaminase autoantibodies with antiendomysium antibodies in pediatric and adult patients with celiac disease. Allergy. 2001;56(6):544-547. Not about consequences of testing. [pmid: 11421901].
Salur L, Uibo O, Talvik I, et al. The high frequency of coeliac disease among children with neurological disorders. European Journal of Neurology - the Official Journal of the European Federation of Neurological Societies. 2000;7(6):707-711. Not about consequences of testing. [pmid: 11136360].
Sandberg-Bennich S, Dahlquist G, Kallen B. Coeliac disease is associated with intrauterine growth and neonatal infections. Acta Paediatr. 2002;91(1):30-33. Not about consequences of testing. [pmid: 11883814].
Sanders D S. Coeliac disease. Br J Surg. 2002;89(6):676-677. Not about consequences of testing. [pmid: 12027975].
Sanders David S, Patel Dina, Stephenson Timothy J, et al. A primary care cross-sectional study of undiagnosed adult coeliac disease. Eur J Gastroenterol Hepatol. 2003;15(4):407-413. Not about consequences of testing. [pmid: 12655262].
Sardy M, Karpati S, Peterfy F, et al. Comparison of a tissue transglutaminase ELISA with the endomysium antibody test in the diagnosis of gluten-sensitive enteropathy. Z Gastroenterol. 2000;38(5):357-364. Not about consequences of testing. [pmid: 10875144].
Sardy M, Odenthal U, Karpati S, et al. Recombinant human tissue transglutaminase ELISA for the diagnosis of gluten-sensitive enteropathy. Clin Chem. 1999;45(12):2142-2149. Not about consequences of testing. [pmid: 10585346].
Sategna Guidetti C, Solerio E, Scaglione N, et al. Duration of gluten exposure in adult coeliac disease does not correlate with the risk for autoimmune disorders. Gut. 2001;49(4):502-505. Not about consequences of testing. [pmid: 11559646]. [pmcid: 1728461].
Sategna Guidetti, Carla Scaglione, Nadia Martini, et al. Red cell distribution width as a marker of coeliac disease: a prospective study. Eur J Gastroenterol Hepatol. 2002;14(2):177-181. Not about consequences of testing. [pmid: 11981342].
Sategna-Guidetti C, Bruno M, Mazza E, et al. Autoimmune thyroid diseases and coeliac disease. Eur J Gastroenterol Hepatol. 1998;10(11):927-931. Not about consequences of testing. [pmid: 9872614].
Sategna-Guidetti C, Grosso S B, Bruno M, et al. Indirect immunofluorescence for of anti-jejunum antibody detection in celiac disease: comparison among different antigenic substrates. Panminerva Med. 1998;40(4):261-263. Not about consequences of testing. [pmid: 9973817].
Sategna-Guidetti C, Grosso S B, Bruno M, et al. Is human umbilical cord the most suitable substrate for the detection of endomysium antibodies in the screening and follow-up of coeliac disease?. Eur J Gastroenterol Hepatol. 1997;9(7):657-660. Not about consequences of testing. [pmid: 9262972].
Sategna-Guidetti C, Grosso S, Bruno M, et al. Comparison of serum anti-gliadin, anti-endomysium, and anti-jejunum antibodies in adult celiac sprue. J Clin Gastroenterol. 1995;20(1):17-21. Not about consequences of testing. [pmid: 7884170].
Sategna-Guidetti C, Grosso S, Pulitano R, et al. Celiac disease and insulin-dependent diabetes mellitus. Screening in an adult population. Dig Dis Sci. 1994;39(8):1633-1637. Not about consequences of testing. [pmid: 8050311].
Sategna-Guidetti C, Grosso S. Changing pattern in adult coeliac disease: A 24-year survey. Eur J Gastroenterol Hepatol. 1994;6(1):15-19. Not about consequences of testing.
Sategna-Guidetti C, Pulitano R, Grosso S, et al. Serum IgA antiendomysium antibody titers as a marker of intestinal involvement and diet compliance in adult celiac sprue. J Clin Gastroenterol. 1993;17(2):123-127. Not about consequences of testing. [pmid: 8409314].
Saukkonen T, Ilonen J, Akerblom H K, et al. Prevalence of coeliac disease in siblings of patients with Type I diabetes is related to the prevalence of DQB1*02 allele. Diabetologia. 2001;44(8):1051-1053. Not about consequences of testing. [pmid: 11484084].
Saukkonen T, Savilahti E, Reijonen H, et al. Coeliac disease: frequent occurrence after clinical onset of insulin-dependent diabetes mellitus. Childhood Diabetes in Finland Study Group. Diabet Med. 1996;13(5):464-470. Not about consequences of testing. [pmid: 8737029].
Saverymuttu S H, Sabbat J, Burke M, et al. Impact of endoscopic duodenal biopsy on the detection of small intestinal villous atrophy. Postgrad Med J. 1991;67(783):47-49. Not about consequences of testing. [pmid: 2057427].
Sblattero D, Berti I, Trevisiol C, et al. Human recombinant tissue transglutaminase ELISA: an innovative diagnostic assay for celiac disease. Am J Gastroenterol. 2000;95(5):1253-1257. Not about consequences of testing. [pmid: 10811336].
Schaad U, Gaze H, Hadorn B. Value of 1-hour blood-xylose test in diagnosis of childhood coeliac disease. Arch Dis Child. 1978;53(5):420-422. Not about consequences of testing. [pmid: 718246].
Schenk E A, Samloff I M, Klipstein F A. Morphologic characteristics of jejunal biopsy in celiac disease and tropical sprue. Am J Pathol. 1965;47(5):765-781. Not about consequences of testing. [pmid: 5843417].
Schmitz J. Is celiac disease a lifelong disorder?. Clin Invest Med. 1996;19(5):352-356. Not about consequences of testing. [pmid: 8889273].
Schober E, Bittmann B, Granditsch G, et al. Screening by anti-endomysium antibody for celiac disease in diabetic children and adolescents in Austria. J Pediatr Gastroenterol Nutr. 2000;30(4):391-396. Not about consequences of testing. [pmid: 10776949].
Schober Edith, Rami Birgit, Granditsch Gerhard, et al. Coeliac disease in children and adolescents with type 1 diabetes mellitus: to screen or not, to treat or not?. Horm Res. 2002;57(Suppl 1):97-100. Not about consequences of testing. [pmid: 11979035].
Schuppan D, Hahn E G. IgA anti-tissue transglutaminase: setting the stage for coeliac disease screening. Eur J Gastroenterol Hepatol. 2001;13(6):635-637. Not about consequences of testing. [pmid: 11434587].
Schwartz F C M, Lunat M, Wolfsdorf J. Blood xylose concentrations in protein energy malnutrition. Relationship to serum albumin and jejunal histology. S Afr Med J. 1974;48(58):2387-2390. Not about consequences of testing. [pmid: 4215162].
Scoglio Riccardo, Di Pasquale, Giuseppe Pagano, et al. Is intestinal biopsy always needed for diagnosis of celiac disease?. Am J Gastroenterol. 2003;98(6):1325-1331. Not about consequences of testing. [pmid: 12818277].
Scott E M, Scott B B. A strategy for osteoporosis in gastroenterology. Eur J Gastroenterol Hepatol. 1998;10(8):689-696. Not about consequences of testing. [pmid: 9744699].
Scott H, Ek J, Havnen J, et al. Serum antibodies to dietary antigens: a prospective study of the diagnostic usefulness in celiac disease of children. J Pediatr Gastroenterol Nutr. 1990;11(2):215-220. Not about consequences of testing. [pmid: 2395062].
Scott H, Fausa O, Ek J, et al. Measurements of serum IgA and IgG activities to dietary antigens. A prospective study of the diagnostic usefulness in adult coeliac disease. Scand J Gastroenterol. 1990;25(3):287-292. Not about consequences of testing. [pmid: 2320948].
Seah P P, Fry L, Holborow E J, et al. Antireticulin antibody: incidence and diagnostic significance. Gut. 1973;14(4):311-315. Not about consequences of testing. [pmid: 4574903]. [pmcid: 1412607].
Sedghizadeh Parish P, Shuler Charles F, Allen Carl M, et al. Celiac disease and recurrent aphthous stomatitis: a report and review of the literature. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2002;94(4):474-478. Not about consequences of testing. [pmid: 12374923].
Seissler J, Boms S, Wohlrab U, et al. Antibodies to human recombinant tissue transglutaminase measured by radioligand assay: evidence for high diagnostic sensitivity for celiac disease. Horm Metab Res. 1999;31(6):375-379. Not about consequences of testing. [pmid: 10437627].
Selby W S, Gallagher N D. Malignancy in a 19-year experience of adult celiac disease. Dig Dis Sci. 1979;24(9):684-688. Not about consequences of testing. [pmid: 487922].
Selby W S, Painter D, Collins A, et al. Persistent mucosal abnormalities in coeliac disease are not related to the ingestion of trace amounts of gluten. Scand J Gastroenterol. 1999;34(9):909-914. Not about consequences of testing. [pmid: 10522611].
Selby W. Gluten enteropathy. Aust Prescr 2001;24(2):38–40+47. Not about consequences of testing
Semrad C E. Bone mass and gastrointestinal disease. Ann N Y Acad Sci 2000;904564–570. Not about consequences of testing
Seraphin P, Mobarhan S. Mortality in patients with celiac disease. Nutr Rev. 2002;60(4):116-118. Not about consequences of testing. [pmid: 12002682].
Shafer R B, Onstad G R. Measurement of fat absorption utilizing 131iodine-triolein and nonabsorbable radioactive markers. Am J Med Sci. 1975;269(3):327-331. Not about consequences of testing. [pmid: 1155491].
Shahbazkhani Bijan, Malekzadeh Reza, Sotoudeh Masoud, et al. High prevalence of coeliac disease in apparently healthy Iranian blood donors. Eur J Gastroenterol Hepatol. 2003;15(5):475-478. Not about consequences of testing. [pmid: 12702902].
Shaker J L, Brickner R C, Findling J W, et al. Hypocalcemia and skeletal disease as presenting features of celiac disease. Arch Intern Med. 1997;157(9):1013-1016. Not about consequences of testing. [pmid: 9140273].
Shamir Raanan, Lerner Aaron, Shinar Eilat, et al. The use of a single serological marker underestimates the prevalence of celiac disease in Israel: a study of blood donors. Am J Gastroenterol. 2002;97(10):2589-2594. Not about consequences of testing. [pmid: 12385444].
Sheldon W. Prognosis in early adult life of coeliac children treated with a gluten-free diet. Br Med J. 1969;2(654):401-404. Unable to obtain article. [pmid: 5781486]. [pmcid: 1983338].
Shelley J M, Irwig L M, Simpson J M, et al. Evaluation of a mass-media-led campaign to increase Pap smear screening. Health Educ Res. 1991;6(3):267-277. Not about consequences of testing. [pmid: 10148692].
Sher K S, Mayberry J F. Female fertility, obstetric and gynaecological history in coeliac disease. A case control study. Digestion. 1994;55(4):243-246. Not about consequences of testing. [pmid: 8063029].
Sherr H P, Sasaki Y, Newman A, et al. Detection of bacterial deconjugation of bile salts by a convenient breath-analysis technic. N Engl J Med. 1971;285(12):656-661. Not about consequences of testing. [pmid: 4998203].
Shidrawi R G, Przemioslo R, Davies D R, et al. Pitfalls in diagnosing coeliac disease. Am J Clin Pathol. 1994;47(8):693-694. Not about consequences of testing.
Shmerling D H, Franckx J. Childhood celiac disease: a long-term analysis of relapses in 91 patients. J Pediatr Gastroenterol Nutr. 1986;5(4):565-569. Not about consequences of testing. [pmid: 3735007].
Signer E, Burgin-Wolff A, Berger R, et al. Antibodies to gliadin as a screening test for coeliac disease. A prospective study. Helv Paediatr Acta. 1979;34(1):41-52. Not about consequences of testing. [pmid: 372144].
Signore A, Chianelli M, Annovazzi A, et al. Imaging active lymphocytic infiltration in coeliac disease with iodine-123-interleukin-2 and the response to diet. Eur J Nucl Med. 2000;27(1):18-24. Not about consequences of testing. [pmid: 10654142].
Sigurs N, Hattevig G, Kjellman B, et al. Appearance of atopic disease in relation to serum IgE antibodies in children followed up from birth for 4 to 15 years. J Allergy Clin Immunol. 1994;94(4):757-763. Not about consequences of testing. [pmid: 7930310].
Sikora K, Anand B S, Truelove S C, et al. Stimulation of lymphocytes from patients with coeliac disease by a subfraction of gluten. Lancet. 1976;2(7982):389-391. Not about consequences of testing. [pmid: 73852].
Silano M, De Vincenzi M. In vitro screening of food peptides toxic for coeliac and other gluten-sensitive patients: a review. Toxicology. 1999;132(23):99-110. Not about consequences of testing. [pmid: 10433373].
Simko V. Fecal fat microscopy. Acceptable predictive value in screening for steatorrhea. Am J Gastroenterol. 1981;75(3):204-208. Not about consequences of testing. [pmid: 7234842].
Sinclair D, Pearce C B, Saas M S L, et al. A comparative study of tissue transglutaminase antibodies and endomysium antibody immunofluorescence in routine clinical laboratory practice. Ann Clin Biochem. 2003;40(4):411-416. Not about consequences of testing. [pmid: 12880544].
Sjoberg K, Alm R, Ivarsson S A, et al. Prevalence and clinical significance of gliadin antibodies in healthy children and adults. Scand J Gastroenterol. 1994;29(3):248-254. Not about consequences of testing. [pmid: 8209185].
Sjoberg K, Eriksson K F, Bredberg A, et al. Screening for coeliac disease in adult insulin-dependent diabetes mellitus. J Intern Med. 1998;243(2):133-140. Not about consequences of testing. [pmid: 9566642].
Sjoberg K, Eriksson S, Tenngart B, et al. Factor XIII and tissue transglutaminase antibodies in coeliac and inflammatory bowel disease. Autoimmunity. 2002;35(5):357-364. Not about consequences of testing. [pmid: 12515290].
Sjoberg K, Eriksson S. Regional differences in coeliac disease prevalence in Scandinavia?. Scand J Gastroenterol. 1999;34(1):41-45. Not about consequences of testing. [pmid: 10048731].
Sjoberg K, Lindgren S, Eriksson S. Frequent occurrence of non-specific gliadin antibodies in chronic liver disease. Endomysial but not gliadin antibodies predict coeliac disease in patients with chronic liver disease. Scand J Gastroenterol. 1997;32(11):1162-1167. Not about consequences of testing. [pmid: 9399399].
Sjoberg K, Wassmuth R, Reichstetter S, et al. Gliadin antibodies in adult insulin-dependent diabetes--autoimmune and immunogenetic correlates. Autoimmunity. 2000;32(4):217-228. Not about consequences of testing. [pmid: 11191281].
Skala I, Krondl A, Vulterinova M, et al. Composition of feces in steatorrhea of different etiology: mutual relationship between the volume of feces, water, dry matter, nitrogen, and fat content. Am J Dig Dis. 1968;13(3):204-212. Not about consequences of testing. [pmid: 5689417].
Skovbjerg H, Sjostrom H, Noren O B. Coeliac disease - A diagnostic and scientific challenge. Ugeskr Laeg. 2002;164(25):3329-3333. Not about consequences of testing. [pmid: 12107945].
Smecuol E, Vazquez H, Sugai E, et al. Sugar tests detect celiac disease among first-degree relatives. Am J Gastroenterol. 1999;94(12):3547-3552. Not about consequences of testing. [pmid: 10606317].
Smith S E, Littlewood J M. The two-film barium meal in the exclusion of coeliac disease. Clin Radiol. 1977;28(6):629-634. Not about consequences of testing. [pmid: 589918].
Smith S. Jejunal biopsy--seeking an alternative. Paediatr Nurs. 1996;8(4):17-19. Not about consequences of testing. [pmid: 8716795].
Sobel Judith, Curtin Ann, Fell Deborah. The Oregon Breast Cancer Detection and Awareness Project: The legacy of a mammogram screening campaign. Health Values. 1991;15(1):3-8. Not about consequences of testing.
Sollid L M, Scott H. New tool to predict celiac disease on its way to the clinics. Gastroenterology. 1998;115(6):1584-1586. Not about consequences of testing. [pmid: 9834289].
Somech R, Spirer Z. Celiac disease: extraintestinal manifestations, associated diseases, and complications. Adv Pediatr. 2002;49:191-201. Not about consequences of testing. [pmid: 12214771].
Sorell L, Garrote J A, Acevedo B, et al. One-step immunochromatographic assay for screening of coeliac disease. Lancet. 2002;359(9310):945-946. Not about consequences of testing. [pmid: 11918916].
Sorensen H T, Fonager K. Risk estimation of disorders associated with coeliac disease. A 16-year Danish nationwide follow-up study based on hospital discharge data. Implications for screening. Int J Risk Saf Med. 1996;8(2):137-140. Not about consequences of testing.
Soresi M, Amplo M, Agliastro R, et al. Screening for autoantibodies to tissue transglutaminase reveals a low prevalence of celiac disease in blood donors with cryptogenic hypertransaminasemia. Digestion. 2001;64(2):87-91. Not about consequences of testing. [pmid: 11684821].
Spiekerkoetter U, Seissler J, Wendel U. General screening for celiac disease is advisable in children with type 1 diabetes. Horm Metab Res. 2002;34(4):192-195. Not about consequences of testing. [pmid: 11987028].
Stahlberg M R, Savilahti E, Viander M. Antibodies to gliadin by ELISA as a screening test for childhood celiac disease. J Pediatr Gastroenterol Nutr. 1986;5(5):726-729. Not about consequences of testing. [pmid: 3761105].
Stazi A V, Mantovani A. A risk factor for female fertility and pregnancy: celiac disease. Gynecological Endocrinology - the Official Journal of the International Society of Gynecological Endocrinology 2000;14(6):454–463 Not about consequences of testing
Stenhammar L, Ascher H, Danielsson L, et al. Small bowel biopsy in Swedish paediatric clinics. Acta Paediatr. 2002;91(10):1126-1129. Not about consequences of testing. [pmid: 12434901].
Stenhammar L. Transient gastro-intestinal disorders during infancy and early childhood. A follow-up study with special reference to coeliac disease. Acta Paediatr Scand. 1981;70(3):383-387. Not about consequences of testing. [pmid: 7246130].
Stern M, Ciclitira P J, van Eckert R, et al. Analysis and clinical effects of gluten in coeliac disease. Eur J Gastroenterol Hepatol. 2001;13(6):741-747. Not about consequences of testing. [pmid: 11434606].
Stern M, Fischer K, Gruettner R. Gliadin antibodies in coeliac disease. Acta Paediatr Belg. 1977;30(4):252. Not about consequences of testing.
Stern M, Teuscher M, Wechmann T. Serological screening for coeliac disease: methodological standards and quality control. Acta Paediatr. 1996;412(Suppl):49-51. Not about consequences of testing.
Stern M. Comparative evaluation of serologic tests for celiac disease: a European initiative toward standardization. J Pediatr Gastroenterol Nutr. 2000;31(5):513-519. Not about consequences of testing. [pmid: 11144436].
Stevens F M, Lloyd R S, Geraghty S M, et al. Schizophrenia and coeliac disease--the nature of the relationship. Psychol Med. 1977;7(2):259-263. Not about consequences of testing. [pmid: 877189].
Stevens F M, Lloyd R, Egan-Mitchell B, et al. Reticulin antibodies in patients with coeliac disease and their relatives. Gut. 1975;16(8):598-602. Not about consequences of testing. [pmid: 1102397]. [pmcid: 1411013].
Stewart J. Child coeliacs in adult life. Ir Med J. 1974;67(15):411-414. Not about consequences of testing. [pmid: 4412415].
Stockbrugger R W, Armbrecht U, Muller E, et al. Determination of faecal chymotrypsin concentration and 72-hour faecal chymotrypsin output in the detection of pancreatic steatorrhoea. Scand J Gastroenterol. 1991;188(Suppl):13-19. Not about consequences of testing.
Stocker W, Otte M, Ulrich S, et al. Autoimmunity to pancreatic juice in Crohn's disease. Results of an autoantibody screening in patients with chronic inflammatory bowel disease. Scand J Gastroenterol. 1987;139(Suppl):41-52. Not about consequences of testing.
Storm W. Celiac disease and alopecia areata in a child with Down Syndrome. J Intellect Disabil Res. 2000;44(5):621-623. Not about consequences of testing. [pmid: 11079358].
Storsrud S, Olsson M, Arvidsson Lenner R, et al. Adult coeliac patients do tolerate large amounts of oats. Eur J Clin Nutr. 2003;57(1):163-169. Not about consequences of testing. [pmid: 12548312].
Storsrud Stine, Hulthen Lena R, Lenner Ragnhild A. Beneficial effects of oats in the gluten-free diet of adults with special reference to nutrient status, symptoms and subjective experiences. Br J Nutr. 2003;90(1):101-107. Not about consequences of testing. [pmid: 12844381].
Straughan P T, Seow A. Barriers to mammography among Chinese women in Singapore: A focus group approach. Health Educ Res. 1995;10(4):431-441. Not about consequences of testing.
Strobel S, Brydon W G, Ferguson A. Cellobiose/mannitol sugar permeability test complements biopsy histopathology in clinical investigation of the jejunum. Gut. 1984;25(11):1241-1246. Not about consequences of testing. [pmid: 6437913]. [pmcid: 1432305].
Stulik J, Hernychova L, Porkertova S, et al. Identification of new celiac disease autoantigens using proteomic analysis. Proteomics. 2003;3(6):951-956. Not about consequences of testing. [pmid: 12833519].
Sugai E, Selvaggio G, Vazquez H, et al. Tissue transglutaminase antibodies in celiac disease: assessment of a commercial kit. Am J Gastroenterol. 2000;95(9):2318-2322. Not about consequences of testing. [pmid: 11007235].
Sugai E, Srur G, Vazquez H, et al. Steatocrit: a reliable semiquantitative method for detection of steatorrhea. J Clin Gastroenterol. 1994;19(3):206-209. Not about consequences of testing. [pmid: 7806830].
Sugai Emilia, Chernavsky Alejandra, Pedreira Silvia, et al. Bone-specific antibodies in sera from patients with celiac disease: characterization and implications in osteoporosis. J Clin Immunol. 2002;22(6):353-362. Not about consequences of testing. [pmid: 12462335].
Suharjono. Intestinal biopsy and coeliac disease. Paediatr Indones. 1971;11(3):116-134. Not about consequences of testing. [pmid: 5154768].
Sulkanen S, Halttunen T, Laurila K, et al. Tissue transglutaminase autoantibody enzyme-linked immunosorbent assay in detecting celiac disease. Gastroenterology. 1998;115(6):1322-1328. Not about consequences of testing. [pmid: 9834257].
Sumnik Z, Kolouskova S, Cinek O, et al. HLA-DQA1*05-DQB1*0201 positivity predisposes to coeliac disease in Czech diabetic children. Acta Paediatr. 2000;89(12):1426-1430. Not about consequences of testing. [pmid: 11195230].
Swain V A, Young W F, Pringle E M. Hypertrophy of the appendices epiploicae and lipomatous polyposis of the colon. Gut. 1969;10(7):587-589. Not about consequences of testing. [pmid: 5806940]. [pmcid: 1552941].
Swinson C M, Slavin G, Coles E C, et al. Coeliac disease and malignancy. Lancet. 1983;1(8316):111-115. Not about consequences of testing. [pmid: 6129425].
Szaflarska-Szczepanik A, Czerwionka-Szaflarska M. The frequency of occurrence and clinical picture of celiac disease in the parents of children with the disease. Medical Science Monitor - International Medical Journal of Experimental and Clinical Research. 2001;7(5):971-976. Not about consequences of testing. [pmid: 11535944].
Tai V, Crowe M, O'Keefe S. Celiac disease in older people. J Am Geriatr Soc. 2000;48(12):1690-1696. Not about consequences of testing. [pmid: 11129763].
Talal A H, Murray J A, Goeken J A, et al. Celiac disease in an adult population with insulin-dependent diabetes mellitus: use of endomysial antibody testing. Am J Gastroenterol. 1997;92(8):1280-1284. Not about consequences of testing. [pmid: 9260789].
Talstad I, Fretheim B, Myren J, et al. Graded gastrectomy for duodenal ulcer -- a five-year prospective study. Scand J Gastroenterol. 1975;33(Suppl):1-27. Not about consequences of testing.
Tandon B N, Iyenger K P, Deo M G, et al. A study of “sprue syndrome in adults” in northern India. J Assoc Physicians India. 1966;14(4):197-202. Not about consequences of testing. [pmid: 5933289].
Tandon B N, Tandon R K, Satpathy B K, et al. Mechanism of malabsorption in giardiasis: a study of bacterial flora and bile salt deconjugation in upper jejunum. Gut. 1977;18(3):176-181. Not about consequences of testing. [pmid: 856675]. [pmcid: 1411381].
Tarmure Simina, Grigorescu Mircea, Cristea Anca, et al. Antiendomysial and antitissue transglutaminase antibodies in gluten-induced enteropathy. Rom J Gastroenterol. 2002;11(2):91-95. Not about consequences of testing. [pmid: 12145663].
Taylor C J. Predictive value of intraepithelial lymphocyte counts in childhood coeliac disease. J Pediatr Gastroenterol Nutr. 1988;7(4):532-536. Not about consequences of testing. [pmid: 3397847].
Tesei N, Sugai E, Vazquez H, et al. Antibodies to human recombinant tissue transglutaminase may detect coeliac disease patients undiagnosed by endomysial antibodies. Aliment Pharmacol Ther. 2003;17(11):1415-1423. Not about consequences of testing. [pmid: 12786636].
Thapa B R. Celiac disease in India. Indian J Pediatr. 1999;66(1 Suppl):S16-S20. Not about consequences of testing. [pmid: 11132463].
Thomas A G, Phillips A D, Walker-Smith J A. The value of proximal small intestinal biopsy in the differential diagnosis of chronic diarrhoea. Arch Dis Child. 1992;67(6):741-743. Not about consequences of testing. [pmid: 1626996].
Thomas D W, Sinatra F R, Merritt R J. Random fecal alpha-1-antitrypsin concentration in children with gastrointestinal disease. Gastroenterology. 1981;80(4):776-782. Not about consequences of testing. [pmid: 6970702].
Thomas P D, Forbes A, Green J, et al. Guidelines for the investigation of chronic diarrhoea, 2nd edition. Gut. 2003;52(Suppl 5):v1-v15. Not about consequences of testing. [pmid: 12801941].
Thompson H. Necropsy studies on adult coeliac disease. Am J Clin Pathol. 1974;27(9):710-721. Not about consequences of testing. [pmid: 4606612].
Thompson J B, Su C K, Ringrose R E, et al. Fecal triglycerides. II. Digestive versus absorptive steatorrhea. J Lab Clin Med. 1969;73(3):521-530. Not about consequences of testing. [pmid: 5766197].
Thornquist H, Jacobsen G S, Dahl L B, et al. Coeliac disease and gluten-free diet: a following-up study of fifteen young adults. Ann Nutr Metab. 1993;37(6):295-301. Not about consequences of testing. [pmid: 8109888].
Tonutti E, Visentini D, Bizzaro N, et al. The role of antitissue transglutaminase assay for the diagnosis and monitoring of coeliac disease: a French-Italian multicentre study. Am J Clin Pathol. 2003;56(5):389-393. Not about consequences of testing.
Tovey F I, Godfrey J E, Lewin M R. A gastrectomy population: 25–30 years on. Postgrad Med J. 1990;66(776):450-456. Not about consequences of testing. [pmid: 2216995].
Townley R R, Anderson C M. Coeliac disease. A review. Ergeb Inn Med Kinderheilkd 1967;261–44. Not about consequences of testing
Tran M, Forget P, Van den, et al. Improved steatocrit results obtained by acidification of fecal homogenates are due to improved fat extraction. J Pediatr Gastroenterol Nutr. 1996;22(2):157-160. Not about consequences of testing. [pmid: 8642488].
Tran M, Forget P, Van den, et al. The acid steatocrit: a much improved method. J Pediatr Gastroenterol Nutr. 1994;19(3):299-303. Not about consequences of testing. [pmid: 7815261].
Trevisiol C, Not T, Berti I, et al. Screening for coeliac disease in healthy blood donors at two immuno-transfusion centres in north-east Italy. Ital J Gastroenterol Hepatol. 1999;31(7):584-586. Not about consequences of testing. [pmid: 10604097].
Trevisiol C, Ventura A, Baldas V, et al. A reliable screening procedure for coeliac disease in clinical practice. Scand J Gastroenterol. 2002;37(6):679-684. Not about consequences of testing. [pmid: 12126246].
Trewby P N, Chipping P M, Palmer S J, et al. Splenic atrophy in adult coeliac disease: is it reversible?. Gut. 1981;22(8):628-632. Not about consequences of testing. [pmid: 7286779]. [pmcid: 1420073].
Trier J S. Diagnostic value of peroral biopsy of the proximal small intestine. N Engl J Med. 1971;285(26):1470-1473. Not about consequences of testing. [pmid: 4107817].
Troncone R, Greco L, Auricchio S. Gluten-sensitive enteropathy. Pediatr Clin North Am. 1996;43(2):355-373. Not about consequences of testing. [pmid: 8614605].
Troncone R, Maurano F, Rossi M, et al. IgA antibodies to tissue transglutaminase: An effective diagnostic test for celiac disease. Eur J Pediatr. 1999;134(2):166-171. Not about consequences of testing.
Troncone R, Starita A, Coletta S, et al. Antigliadin antibody, D-xylose, and cellobiose/mannitol permeability tests as indicators of mucosal damage in children with coeliac disease. Scand J Gastroenterol. 1992;27(8):703-706. Not about consequences of testing. [pmid: 1439555].
Tucker N T, Barghuthy F S, Prihoda T J, et al. Antigliadin antibodies detected by enzyme-linked immunosorbent assay as a marker of childhood celiac disease. Eur J Pediatr. 1988;113(2):286-289. Not about consequences of testing.
Tumer L, Hasanoglu A, Aybay C. Endomysium antibodies in the diagnosis of celiac disease in short-statured children with no gastrointestinal symptoms. Pediatr Int. 2001;43(1):71-73. Not about consequences of testing. [pmid: 11208004].
Tursi A, Brandimarte G, Giorgetti G, et al. Low prevalence of antigliadin and anti-endomysium antibodies in subclinical/silent celiac disease. Am J Gastroenterol. 2001;96(5):1507-1510. Not about consequences of testing. [pmid: 11374690].
Tursi A, Brandimarte G, Giorgetti G M, et al. Effectiveness of the sorbitol HSUB2 breath test in detecting histological damage among relatives of coeliacs. Scand J Gastroenterol. 2003;38(7):727-731. Not about consequences of testing. [pmid: 12889558].
Tursi A, Brandimarte G, Giorgetti G M. Sorbitol H2-breath test versus anti-endomysium antibodies for the diagnosis of subclinical/silent coeliac disease. Scand J Gastroenterol. 2001;36(11):1170-1172. Not about consequences of testing. [pmid: 11686216].
Tursi A, Giorgetti G, Brandimarte G, et al. Prevalence and clinical presentation of subclinical/silent celiac disease in adults: an analysis on a 12-year observation. Hepatogastroenterology. 2001;48(38):462-464. Not about consequences of testing. [pmid: 11379333].
Tursi Antonio, Brandimarte Giovanni, Giorgetti Gian, et al. Prevalence of antitissue transglutaminase antibodies in different degrees of intestinal damage in celiac disease. J Clin Gastroenterol. 2003;36(3):219-221. Not about consequences of testing. [pmid: 12590232].
Tursi Antonio, Brandimarte Giovanni. The symptomatic and histologic response to a gluten-free diet in patients with borderline enteropathy. J Clin Gastroenterol. 2003;36(1):13-17. Not about consequences of testing. [pmid: 12488700].
Uibo O, Lambrechts A, Mascart-Lemone F. Human oesophagus: a convenient antigenic substrate for the determination of anti-endomysium antibodies in the serological diagnosis of coeliac disease. Eur J Gastroenterol Hepatol. 1995;7(1):37-40. Not about consequences of testing. [pmid: 7866808].
Uibo O, Maaroos H I. Hospital screening of coeliac disease in Estonian children by anti-gliadin antibodies of IgA class. Acta Paediatr. 1993;82(3):233-234. Not about consequences of testing. [pmid: 8495074].
Uibo O, Metskula K, Kukk T, et al. Results of coeliac disease screening in Estonia in 1990-1994. Acta Paediatr. 1996;412(Suppl):39-41. Not about consequences of testing.
Uibo O, Uibo R, Kleimola V, et al. Serum IgA anti-gliadin antibodies in an adult population sample. High prevalence without celiac disease. Dig Dis Sci. 1993;38(11):2034-2037. Not about consequences of testing. [pmid: 8223078].
Uibo O. Childhood celiac disease in Estonia: efficacy of the IgA-class antigliadin antibody test in the search for new cases. J Pediatr Gastroenterol Nutr. 1994;18(1):53-55. Not about consequences of testing. [pmid: 8126618].
Uil J J, van Elburg R M, Janssens P M, et al. Sensitivity of a hyperosmolar or “low”-osmolar test solution for sugar absorption in recognizing small intestinal mucosal damage in coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2000;32(3):195-200. Not about consequences of testing. [pmid: 10975768].
Uil J J, van Elburg R M, van Overbeek F M, et al. Clinical implications of the sugar absorption test: intestinal permeability test to assess mucosal barrier function. Scand J Gastroenterol. 1997;233(Suppl):70-78. Not about consequences of testing.
Uil J J, van Elburg R M, van Overbeek F M, et al. Follow-up of treated coeliac patients: sugar absorption test and intestinal biopsies compared. Eur J Gastroenterol Hepatol. 1996;8(3):219-223. Not about consequences of testing. [pmid: 8724020].
Unsworth D J, Brown D L. Serological screening suggests that adult coeliac disease is underdiagnosed in the UK and increases the incidence by up to 12%. Gut. 1994;35(1):61-64. Not about consequences of testing. [pmid: 8307451]. [pmcid: 1374633].
Unsworth D J, Johnson G D, Haffenden G, et al. Binding of wheat gliadin in vitro to reticulum in normal and dermatitis herpetiformis skin. J Invest Dermatol. 1981;76(2):88-93. Not about consequences of testing. [pmid: 6161972].
Unsworth D J, Lock R J, Harvey R F. Improving the diagnosis of coeliac disease in anaemic women. Br J Haematol. 2000;111(3):898-901. Not about consequences of testing. [pmid: 11122153].
Usai P, Boi M F, Piga M, et al. Adult celiac disease is frequently associated with sacroiliitis. Dig Dis Sci. 1995;40(9):1906-1908. Not about consequences of testing. [pmid: 7555441].
Usai P, Minerba L, Marini B, et al. Case control study on health-related quality of life in adult coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(8):547-552. Not about consequences of testing. [pmid: 12502210].
Usselmann B, Loft D E. An easy test for coeliac disease using human umbilical vein endothelial cells. Eur J Gastroenterol Hepatol. 1996;8(10):947-950. Not about consequences of testing. [pmid: 8930556].
Ussher R, Yeong M L, Stace N. Coeliac disease: incidence and prevalence in Wellington 1985-92. N Z Med J. 1994;107(978):195-197. Not about consequences of testing. [pmid: 8196863].
Vahedi Kouroche, Mascart Francoise, Mary Jean, et al. Reliability of antitransglutaminase antibodies as predictors of gluten-free diet compliance in adult celiac disease. Am J Gastroenterol. 2003;98(5):1079-1087. Not about consequences of testing. [pmid: 12809831].
Valdimarsson T, Franzen L, Grodzinsky E, et al. Is small bowel biopsy necessary in adults with suspected celiac disease and IgA anti-endomysium antibodies? 100% positive predictive value for celiac disease in adults. Dig Dis Sci. 1996;41(1):83-87. Not about consequences of testing. [pmid: 8565771].
Valdimarsson T, Toss G, Ross I, et al. Bone mineral density in coeliac disease. Scand J Gastroenterol. 1994;29(5):457-461. Not about consequences of testing. [pmid: 8036462].
Valentini R A, Andreani M L, Corazza G R, et al. IgA endomysium antibody: a valuable tool in the screening of coeliac disease but not its follow-up. Ital J Gastroenterol. 1994;26(6):279-282. Not about consequences of testing. [pmid: 7949263].
Valentino R, Savastano S, Tommaselli A P, et al. Prevalence of coeliac disease in patients with thyroid autoimmunity. Horm Res. 1999;51(3):124-127. Not about consequences of testing. [pmid: 10461017].
Valletta E A, Trevisiol D, Mastella G. IgA anti-gliadin antibodies in the monitoring of gluten challenge in celiac disease. J Pediatr Gastroenterol Nutr. 1990;10(2):169-173. Not about consequences of testing. [pmid: 2303968].
Van Belzen M J, Meijer J W R, Sandkuijl L A, et al. A major non-HLA locus in celiac disease maps to chromosome 19. Gastroenterology. 2003;125(4):1032-1041. Not about consequences of testing. [pmid: 14517787].
van den, Bosch H C, Tham R T, et al. Celiac disease: small-bowel enteroclysis findings in adult patients treated with a gluten-free diet. Radiology. 1996;201(3):803-808. Not about consequences of testing. [pmid: 8939235].
Van den, Neucker A M, Kerkvliet E M, et al. Acid steatocrit: a reliable screening tool for steatorrhoea. Acta Paediatr. 2001;90(8):873-875. Not about consequences of testing. [pmid: 11529533].
Van den, Neucker A, Pestel N, et al. Clinical use of acid steatocrit. Acta Paediatr. 1997;86(5):466-469. Not about consequences of testing. [pmid: 9183483].
van Lith, Marcel van, Ham Marieke, et al. Novel polymorphisms in HLA-DOA and HLA-DOB in B-cell malignancies. Immunogenetics. 2002;54(8):591-595. Not about consequences of testing. [pmid: 12439622].
van Overbeek F M, Uil-Dieterman I G, Mol I W, et al. The daily gluten intake in relatives of patients with coeliac disease compared with that of the general Dutch population. Eur J Gastroenterol Hepatol. 1997;9(11):1097-1099. Not about consequences of testing. [pmid: 9431901].
Van Wouwe J P. Clinical and laboratory diagnosis of acrodermatitis enteropathica. Eur J Pediatr. 1989;149(1):2-8. Not about consequences of testing. [pmid: 2691254].
Vancikova Z, Chlumecky V, Sokol D, et al. The serologic screening for celiac disease in the general population (blood donors) and in some high-risk groups of adults (patients with autoimmune diseases, osteoporosis and infertility) in the Czech republic. Folia Microbiol (Praha). 2002;47(6):753-758. Not about consequences of testing. [pmid: 12630332].
Vanderschueren-Lodeweyckx M, Wolter R, Malvaux P, et al. The glucagon stimulation test: effect of plasma growth hormone and on immunoreactive insulin, cortisol, and glucose in children. Eur J Pediatr. 1974;85(2):182-187. Not about consequences of testing.
Varjonen E, Vainio E, Kalimo K. Antigliadin IgE--indicator of wheat allergy in atopic dermatitis. Allergy. 2000;55(4):386-391. Not about consequences of testing. [pmid: 10782525].
Varkonyi A, Boda M, Endreffy E, et al. Coeliac disease: always something to discover. Scand J Gastroenterol. 1998;228(Suppl):122-129. Not about consequences of testing.
Varma S, Malhotra P, Kochhar R, et al. Celiac disease presenting as iron-deficiency anemia in northern India. Indian Journal of Gastroenterology - Official Journal of the Indian Society of Gastroenterology. 2001;20(6):234-236. Not about consequences of testing. [pmid: 11817777].
Vazquez H, Cabanne A, Sugai E, et al. Serological markers identify histologically latent coeliac disease among first-degree relatives. Eur J Gastroenterol Hepatol. 1996;8(1):15-21. Not about consequences of testing. [pmid: 8900904].
Vazquez H, Sugai E, Pedreira S, et al. Screening for asymptomatic celiac sprue in families. J Clin Gastroenterol. 1995;21(2):130-133. Not about consequences of testing. [pmid: 8583078].
Ventrucci M, Cipolla A, Di Stefano M, et al. Determination of fecal fat concentration by near infrared spectrometry for the screening of pancreatic steatorrhea. International Journal of Pancreatology - Official Journal of the International Association of Pancreatology. 1998;23(1):17-23. Not about consequences of testing. [pmid: 9520087].
Ventura A, Magazzu G, Greco L. Duration of exposure to gluten and risk for autoimmune disorders in patients with celiac disease. SIGEP Study Group for Autoimmune Disorders in Celiac Disease. Gastroenterology. 1999;117(2):297-303. Not about consequences of testing. [pmid: 10419909].
Ventura A, Martelossi S. The old and new coeliac disease. Eur J Pediatr Dermatol. 1995;5(2):87-94. Not about consequences of testing.
Verhulst M L, Dur A H M, Driessen W M M. Two sisters with coeliac disease and jejunal cancer: Just a coincidence?. Neth J Med. 1993;42(1):16-20. Not about consequences of testing. [pmid: 8446219].
Vermeer B J, Lindeman J, Harst-Oostveen C J, et al. The immunoglobulin-bearing cells in the lamina propria and the clinical response to a gluten-free diet in dermatitis herpetiformis. Arch Dermatol Res. 1977;258(3):223-230. Not about consequences of testing. [pmid: 329776].
Vesy C J, Greenson J K, Papp A C, et al. Evaluation of celiac disease biopsies for adenovirus 12 DNA using a multiplex polymerase chain reaction. Modern Pathology - an Official Journal of the United States and Canadian Academy of Pathology, Inc. 1993;6(1):61-64. Not about consequences of testing. [pmid: 8381233].
Viner Mark W, Waite John, Thienhaus Ole J. Comorbidity and the need for physical examinations among patients seen in the psychiatric emergency service. Psychiatr Serv. 1996;47(9):947-948. Not about consequences of testing. [pmid: 8875658].
Visakorpi J K, Kuitunen P, Pelkonen P. Intestinal malabsorption: a clinical study of 22 children over 2 years of age. Acta Paediatr Scand. 1970;59(3):273-280. Not about consequences of testing. [pmid: 5444711].
Visakorpi J K, Kuitunen P, Savilahti E. Frequency and nature of relapses in children suffering from the malabsorption syndrome with gluten intolerance. Acta Paediatr Scand. 1970;59(5):481-486. Not about consequences of testing. [pmid: 5455517].
Visakorpi J K, Maki M. Changing clinical features of coeliac disease. Acta Paediatr Suppl. 1994;83(395):10-13. Not about consequences of testing. [pmid: 8025351].
Vitoria J C, Arrieta A, Arranz C, et al. Antibodies to gliadin, endomysium, and tissue transglutaminase for the diagnosis of celiac disease. J Pediatr Gastroenterol Nutr. 1999;29(5):571-574. Not about consequences of testing. [pmid: 10554125].
Vitoria J C, Arrieta A, Astigarraga I, et al. Use of serological markers as a screening test in family members of patients with celiac disease. J Pediatr Gastroenterol Nutr. 1994;19(3):304-309. Not about consequences of testing. [pmid: 7815262].
Vitoria J C, Arrieta A, Ortiz L, et al. Antibodies to human tissue transglutaminase for the diagnosis of celiac disease. J Pediatr Gastroenterol Nutr. 2001;33(3):349-350. Not about consequences of testing. [pmid: 11593137].
Vitoria J C, Castano L, Rica I, et al. Association of insulin-dependent diabetes mellitus and celiac disease: a study based on serologic markers. J Pediatr Gastroenterol Nutr. 1998;27(1):47-52. Not about consequences of testing. [pmid: 9669725].
Vivas Santiago, Ruiz de, Morales Jose M, et al. Human recombinant anti-transglutaminase antibody testing is useful in the diagnosis of silent coeliac disease in a selected group of at-risk patients. Eur J Gastroenterol Hepatol. 2003;15(5):479-483. Not about consequences of testing. [pmid: 12702903].
Vjero Katerina, Martucci Susi, Alvisi Costanza, et al. Defining a proper setting for endoscopy in coeliac disease. Eur J Gastroenterol Hepatol. 2003;15(6):675-678. Not about consequences of testing. [pmid: 12840680].
Vogelsang H, Genser D, Wyatt J, et al. Screening for celiac disease: a prospective study on the value of noninvasive tests. Am J Gastroenterol. 1995;90(3):394-398. Not about consequences of testing. [pmid: 7872276].
Vogelsang H, Schwarzenhofer M, Oberhuber G. Changes in gastrointestinal permeability in celiac disease. Dig Dis. 1998;16(6):333-336. Not about consequences of testing. [pmid: 10207219].
Vogelsang H, Wyatt J, Penner E, et al. Screening for celiac disease in first-degree relatives of patients with celiac disease by lactulose/mannitol test. Am J Gastroenterol. 1995;90(10):1838-1842. Not about consequences of testing. [pmid: 7572905].
Vogelsang H. The changing features of celiac disease. Preface. Dig Dis. 1998;16(6):328-329. Not about consequences of testing. [pmid: 10357615].
Volta U, De Franceschi L, Lari F, et al. Coeliac disease hidden by cryptogenic hypertransaminasaemia. Lancet. 1998;352(9121):26-29. Not about consequences of testing. [pmid: 9800742].
Volta U, De Franceschi L, Molinaro N, et al. Frequency and significance of anti-gliadin and anti-endomysial antibodies in autoimmune hepatitis. Dig Dis Sci. 1998;43(10):2190-2195. Not about consequences of testing. [pmid: 9790453].
Volta U, Granito A, De Franceschi L, et al. Anti tissue transglutaminase antibodies as predictors of silent coeliac disease in patients with hypertransaminasaemia of unknown origin. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2001;33(5):420-425. Not about consequences of testing. [pmid: 11529654].
Volta U, Lazzari R, Guidetti C S, et al. Multicenter study on the reproducibility of antigliadin (AGA) and antiendomysial antibodies (EmA) in celiac sprue screening. The Tenue Club Group. J Clin Gastroenterol. 1994;19(1):81-82. Not about consequences of testing. [pmid: 7930442].
Volta U, Lenzi M, Lazzari R, et al. Antibodies to gliadin detected by immunofluorescence and a micro-ELISA method: markers of active childhood and adult coeliac disease. Gut. 1985;26(7):667-671. Not about consequences of testing. [pmid: 3894169]. [pmcid: 1432992].
Volta U, Molinaro N, De Franceschi L, et al. Human umbilical cord as substrate for IgA antiendomysial antibodies allows large scale screening for celiac sprue. J Clin Gastroenterol. 1996;23(1):18-20. Not about consequences of testing. [pmid: 8835893].
Volta U, Molinaro N, De Franceschi L, et al. IgA anti-endomysial antibodies on human umbilical cord tissue for celiac disease screening. Save both money and monkeys. Dig Dis Sci. 1995;40(9):1902-1905. Not about consequences of testing. [pmid: 7555440].
Volta U, Molinaro N, De Franchis R, et al. Correlation between IgA antiendomysial antibodies and subtotal villous atrophy in dermatitis herpetiformis. J Clin Gastroenterol. 1992;14(4):298-301. Not about consequences of testing. [pmid: 1607605].
Volta U, Molinaro N, Fratangelo D, et al. IgA antibodies to jejunum. Specific immunity directed against target organ of gluten-sensitive enteropathy. Dig Dis Sci. 1994;39(9):1924-1929. Not about consequences of testing. [pmid: 8082498].
Volta U, Molinaro N, Fusconi M, et al. IgA antiendomysial antibody test. A step forward in celiac disease screening. Dig Dis Sci. 1991;36(6):752-756. Not about consequences of testing. [pmid: 2032516].
Volta U, Ravaglia G, Granito A, et al. Coeliac disease in patients with autoimmune thyroiditis. Digestion. 2001;64(1):61-65. Not about consequences of testing. [pmid: 11549838].
Volta Umberto, Rodrigo Luis, Granito Alessandro, et al. Celiac disease in autoimmune cholestatic liver disorders. Am J Gastroenterol. 2002;97(10):2609-2613. Not about consequences of testing. [pmid: 12385447].
Vuoristo M, Tilvis R, Miettinen T A. Serum plant sterols and lathosterol related to cholesterol absorption in coeliac disease. Clin Chim Acta. 1988;174(2):213-224. Not about consequences of testing. [pmid: 3383445].
Wagner Mary H, Bowser Ellen K, Sherman James M, et al. Comparison of steatocrit and fat absorption in persons with cystic fibrosis. J Pediatr Gastroenterol Nutr. 2002;35(2):202-205. Not about consequences of testing. [pmid: 12187298].
Wahab P J, Meijer J W R, Goerres M S, et al. Coeliac disease: changing views on gluten-sensitive enteropathy. Scand J Gastroenterol. 2002;236(Suppl):60-65. Not about consequences of testing.
Wahab P J, Meijer Jos W R, Dumitra D, et al. Coeliac disease: more than villous atrophy. Rom J Gastroenterol. 2002;11(2):121-127. Not about consequences of testing. [pmid: 12145668].
Wahab P J, Meijer Jos W R, Mulder C J J. Histologic follow-up of people with celiac disease on a gluten-free diet: slow and incomplete recovery. Am J Clin Pathol. 2002;118(3):459-463. Not about consequences of testing. [pmid: 12219789].
Walker-Smith J A. Celiac disease and Down syndrome. Eur J Pediatr. 2000;137(6):743-744. Not about consequences of testing.
Walker-Smith J A. Diabetes and coeliac disease. Lancet. 1969;2(7634):1366. Not about consequences of testing. [pmid: 4188128].
Walker-Smith J A. Transient gluten intolerance. Arch Dis Child. 1972;47(251):155. Not about consequences of testing. [pmid: 5046794].
Walker-Smith J. Cow's milk protein intolerance. Transient food intolerance of infancy. Arch Dis Child. 1975;50(5):347-350. Not about consequences of testing. [pmid: 1211956].
Walker-Smith J. Transient gluten intolerance. Arch Dis Child. 1970;45(242):523-526. Not about consequences of testing. [pmid: 5506937].
Walkowiak J, Herzig K H. Fecal elastase-1 is decreased in villous atrophy regardless of the underlying disease. Eur J Clin Invest. 2001;31(5):425-430. Not about consequences of testing. [pmid: 11589722].
Walkowiak Jaroslaw, Herzig Karl, Strzykala Krystyna, et al. Fecal elastase-1 is superior to fecal chymotrypsin in the assessment of pancreatic involvement in cystic fibrosis. Pediatrics. 2002;110(1 Pt 1):E7. Not about consequences of testing. [pmid: 12093988].
Waller S L, Mottaleb A, Wiggins H S, et al. Further observations on the Lundh test meal in the diagnosis of pancreatic disease. Gut. 1971;12(10):869. Not about consequences of testing. [pmid: 5123302].
Ward Jeanette E, Boyle Kate, Redman Selina, et al. Increasing women's compliance with opportunistic cervical cancer screening: A randomized trial. Am J Prev Med. 1991;7(5):285-291. Not about consequences of testing. [pmid: 1790034].
Watson R G, McMillan S A, Dickey W, et al. Detection of undiagnosed coeliac disease with atypical features using antireticulin and antigliadin antibodies. Q J Med. 1992;84(305):713-718. Not about consequences of testing. [pmid: 1303650].
Wauters E A, Jansen J, Houwen R H, et al. Serum IgG and IgA anti-gliadin antibodies as markers of mucosal damage in children with suspected celiac disease upon gluten challenge. J Pediatr Gastroenterol Nutr. 1991;13(2):192-196. Not about consequences of testing. [pmid: 1941413].
Weile B, Grodzinsky E, Skogh T, et al. Screening Danish blood donors for antigliadin and antiendomysium antibodies. Acta Paediatr. 1996;412(Suppl):46. Not about consequences of testing.
Weile B. Aspects of classic symptomatic childhood coeliac disease in Denmark: Retrospectively illustrated by local, regional, and national studies. APMIS Suppl. 2003;111(113):5-46. Not about consequences of testing. [pmid: 14626049].
Weile I, Grodzinsky E, Skogh T, et al. High prevalence rates of adult silent coeliac disease, as seen in Sweden, must be expected in Denmark. APMIS. 2001;109(11):745-750. Not about consequences of testing. [pmid: 11900053].
Weinstein W M, Brow J R, Parker F, et al. The small intestinal mucosa in dermatitis herpetiformis. II. Relationship of the small intestinal lesion to gluten. Gastroenterology. 1971;60(3):362-369. Not about consequences of testing. [pmid: 5554078].
Weinstein W M. Latent celiac sprue. Gastroenterology. 1974;66(4):489-493. Not about consequences of testing. [pmid: 4821074].
Weir D G, Hourihane D O. Coeliac disease during the teenage period: the value of serial serum folate estimations. Gut. 1974;15(6):450-457. Not about consequences of testing. [pmid: 4851068]. [pmcid: 1413001].
Weizman Z, Forstner G G, Gaskin K J, et al. Bentiromide test for assessing pancreatic dysfunction using analysis of para-aminobenzoic acid in plasma and urine. Studies in cystic fibrosis and Shwachman's syndrome. Gastroenterology. 1985;89(3):596-604. Not about consequences of testing. [pmid: 3874804].
Weizman Z, Hamilton J R, Kopelman H R, et al. Treatment failure in celiac disease due to coexistent exocrine pancreatic insufficiency. Pediatrics. 1987;80(6):924-926. Not about consequences of testing. [pmid: 3684405].
West J, Lloyd C A, Hill P G, et al. IgA-antitissue transglutaminase: validation of a commercial assay for diagnosing coeliac disease. Clin Lab. 2002;48(56):241-246. Not about consequences of testing. [pmid: 12071574].
Whitfield C R. Obstetric sprue. J Obstet Gynaecol Br Commonw. 1970;77(7):577-586. Not about consequences of testing. [pmid: 5458768].
Whorwell P J, Alderson M R, Foster K J, et al. Death from ischaemic heart-disease and malignancy in adult patients with coeliac disease. Lancet. 1976;2(7977):113-114. Not about consequences of testing. [pmid: 59182].
Williams A J, Annis P, Lock R J, et al. Evaluation of a high-throughput second antibody radiobinding assay for measuring IgA antibodies to human tissue transglutaminase. J Immunol Methods. 1999;228(12):81-85. Not about consequences of testing. [pmid: 10556545].
Williams A J, Norcross A J, Lock R J, et al. The high prevalence of autoantibodies to tissue transglutaminase in first-degree relatives of patients with type 1 diabetes is not associated with islet autoimmunity. Diabetes Care. 2001;24(3):504-509. Not about consequences of testing. [pmid: 11289476].
Wills A J, Turner B, Lock R J, et al. Dermatitis herpetiformis and neurological dysfunction. J Neurol Neurosurg Psychiatry. 2002;72(2):259-261. Not about consequences of testing. [pmid: 11796779].
Wills A J. The neurology and neuropathology of coeliac disease. Neuropathol Appl Neurobiol. 2000;26(6):493-496. Not about consequences of testing. [pmid: 11123714].
Wilson C, Eade O E, Elstein M, et al. Subclinical coeliac disease and infertility. Br Med J. 1976;2(6029):215-216. Not about consequences of testing. [pmid: 974499].
Wilson F A, Dietschy J M. Differential diagnostic approach to clinical problems of malabsorption. Gastroenterology. 1971;61(6):911-931. Not about consequences of testing. [pmid: 5125690].
Winston A P. Physical assessment of the eating disordered patient. European Eating Disorders Review. 2000;8(2):188-191. Not about consequences of testing.
Wolford George L, Rosenberg Stanley D, Drake Robert E, et al. Evaluation of methods for detecting substance use disorder in persons with severe mental illness. Psychol Addict Behav. 1999;13(4):313-326. Not about consequences of testing.
Wolters Victorien, Vooijs-Moulaert Anne, Burger Huib, et al. Human tissue transglutaminase enzyme linked immunosorbent assay outperforms both the guinea pig based tissue transglutaminase assay and anti-endomysium antibodies when screening for coeliac disease. Eur J Pediatr. 2002;161(5):284-287. Not about consequences of testing. [pmid: 12012226].
Wong R C W, Wilson R J, Steele R H, et al. A comparison of 13 guinea pig and human anti-tissue transglutaminase antibody ELISA kits. Am J Clin Pathol. 2002;55(7):488-494. Not about consequences of testing.
Woolley Niina, Holopainen Paivi, Ollikainen Vesa, et al. A new locus for coeliac disease mapped to chromosome 15 in a population isolate. Hum Genet. 2002;111(1):40-45. Not about consequences of testing. [pmid: 12136234].
Worden John K, Mickey Ruth M, Flynn Brian S, et al. Development of a community breast screening promotion program using baseline data. Am J Prev Med. 1994;23(3):267-275. Not about consequences of testing.
Wray D, Ferguson M M, Mason D K, et al. Recurrent aphthae: treatment with vitamin B12, folic acid, and iron. Br Med J. 1975;2(5969):490-493. Not about consequences of testing. [pmid: 1148667]. [pmcid: 1673414].
Yeboah F A, White D. AlphaB-crystallin expression in celiac disease - a preliminary study. Croat Med J. 2001;42(5):523-526. Not about consequences of testing. [pmid: 11593501].
Yiannakou J Y, Dell'Olio D, Saaka M, et al. Detection and characterisation of anti-endomysial antibody in coeliac disease using human umbilical cord. Int Arch Allergy Immunol. 1997;112(2):140-144. Not about consequences of testing. [pmid: 9030093].
Young G P, Hebbard G S. Diagnostic techniques for small intestinal disease. Curr Opin Gastroenterol. 1992;8(2):232-238. Not about consequences of testing.
Zachor D A, Mroczek-Musulman E, Brown P. Prevalence of celiac disease in Down syndrome in the United States. J Pediatr Gastroenterol Nutr. 2000;31(3):275-279. Not about consequences of testing. [pmid: 10997372].
Zadik Z, Kowarski A. Incidence of neurosecretory dysfunction among children aged 6–14 years in Rehovot, Israel. Acta Paediatr Scand Suppl 1989;34977–83. Not about consequences of testing
Zalev A H, Gardiner G W, Warren R E. NSAID injury to the small intestine. Abdom Imaging. 1998;23(1):40-44. Not about consequences of testing. [pmid: 9437061].
Zauli D, Grassi A, Granito A, et al. Prevalence of silent coeliac disease in atopics. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2000;32(9):775-779. Not about consequences of testing. [pmid: 11215557].
Zhong F, McCombs C C, Olson J M, et al. An autosomal screen for genes that predispose to celiac disease in the western counties of Ireland. Nat Genet. 1996;14(3):329-333. Not about consequences of testing. [pmid: 8896565].
Zipser Robert D, Patel Sunil, Yahya Kareem Z, et al. Presentations of adult celiac disease in a nationwide patient support group. Dig Dis Sci. 2003;48(4):761-764. Not about consequences of testing. [pmid: 12741468].
Zouganelis S, Priest M. Impact of dietary compliance on nutritional status in adult coeliac disease. Gut. 2001;48(Suppl 1):A42. Unable to obtain article.
Zwolak R M. Can duplex ultrasound replace arteriography in screening for mesenteric ischemia?. Semin Vasc Surg. 1999;12(4):252-260. Not about consequences of testing. [pmid: 10651454].

### Objective 5 - Promoting or Monitoring Adherence to a GFD

Abdulkarim A S, Murray J A. Celiac disease. Curr Treat Options Gastroenterol. 2002;5(1):27-38. Not relevant to adherence. [pmid: 11792235].
Addolorato G, Capristo E, Ghittoni G, et al. Anxiety but not depression decreases in coeliac patients after one-year gluten-free diet: a longitudinal study. Scand J Gastroenterol. 2001;36(5):502-506. Not relevant to adherence. [pmid: 11346203].
Addolorato G, Stefanini G F, Capristo E, et al. Anxiety and depression in adult untreated celiac subjects and in patients affected by inflammatory bowel disease: A personality ‘trait’ or a reactive illness?. Hepatogastroenterology. 1996;43(12):1513-1517. Not relevant to adherence. [pmid: 8975957].
Al Bayaty H F, Aldred M J, Walker D M, et al. Salivary and serum antibodies to gliadin in the diagnosis of celiac disease. J Oral Pathol Med. 1989;18(10):578-581. No correlations with other measures. [pmid: 2621654].
Amari A, Grace N C, Fisher W W. Achieving and Maintaining Compliance With the Ketogenic Diet. J Appl Behav Anal. 1995;28(3):341-342. Not relevant to adherence. [pmid: 7592151]. [pmcid: 1279833].
Amin Rakesh, Murphy Nuala, Edge Julie, et al. A longitudinal study of the effects of a gluten-free diet on glycemic control and weight gain in subjects with type 1 diabetes and celiac disease. Diabetes Care. 2002;25(7):1117-1122. Not relevant to adherence. [pmid: 12087007].
Anderson R P, Degano P, Godkin A J, et al. In vivo antigen challenge in celiac disease identifies a single transglutaminase-modified peptide as the dominant A-gliadin T-cell epitope. Nat Med. 2000;6(3):337-342. Not relevant to adherence. [pmid: 10700238].
Andersson H, Bjorkman A C, Gillberg R, et al. Influence of the amount of dietary gluten on gastrointestinal morphology and function in dermatitis herpetiformis. Human Nutrition. Clinical Nutrition. 1984;38(4):279-285. Not sensitivity or specificity of an identified test. [pmid: 6469705].
Andersson H, Mobacken H. Dietary treatment of dermatitis herpetiformis. Eur J Clin Nutr. 1992;46(5):309-315. Not relevant to adherence. [pmid: 1600929].
Andre F, Andre C, Colin L, et al. Role of new allergens and of allergens consumption in the increased incidence of food sensitizations in France. Toxicology. 1994;93(1):77-83. Not relevant to adherence. [pmid: 7974507].
Andrews A. Coeliac disease: new aspects. BNF Nutrition Bulletin. 1999;24(87):66-70. Not relevant to adherence.
Annibale B, Severi C, Chistolini A, et al. Efficacy of gluten-free diet alone on recovery from iron deficiency anemia in adult celiac patients. Am J Gastroenterol. 2001;96(1):132-137. Not relevant to adherence. [pmid: 11197242].
Anonymous. A long-term survey of coeliac disease. Med J Aust 1971;2(20):992Not relevant to adherence
Anonymous. Catch-up growth in celiac disease. Nutr Rev 1973;31(1):13–14. Not relevant to adherence
Anonymous. Celiac disease and how to live with it. Harvard Women's Health Watch 2001;8(9):3–4. Not relevant to adherence
Anonymous. Celiac disease. Am Fam Phys 1998;57(5):1039–1041. Not relevant to adherence
Anonymous. Growing up with coeliac disease. Lancet 1988;2(8622):1231–1232. Not relevant to adherence
Anonymous. Oats safe for coeliac disease patients. Pharm J 2002;268(7185):200Not relevant to adherence
Ansaldi N, Dell'Olio D, Tavassoli K, et al. Dietary habits and social aspects of patients with coeliac disease. Minerva Med. 1992;83(78):439-443. Not relevant to adherence. [pmid: 1522967].
Ansaldi-Balocco N, Malorgio E, Faussone D, et al. Hydrogen breath-test in coeliac disease. Hydrogen excretion is related to jejunal histological changes. Minerva Pediatr. 1994;46(12):569-574. No monitoring measure of interest. [pmid: 7731420].
Ascher H. Paediatric aspects of coeliac disease: old challenges and new ones…. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(3):216-224. Not relevant to adherence. [pmid: 11990395].
Ashkenazi A, Levin S, Idar D, et al. Cellular immunity in children with coeliac disease. Eur J Pediatr. 1982;138(3):250-253. Not relevant to adherence. [pmid: 6749506].
Ashkenazi A. Living with celiac disease. Child Hosp Q. 1989;1(3):265-271. Not relevant to adherence.
Asquith P. Adult coeliac disease and malignancy. Ir Med J. 1974;67(15):417-420. Not relevant to adherence. [pmid: 4411887].
Atkinson K, Tokmakajian S, Watson W, et al. Evaluation of the endomysial antibody for celiac disease: operating properties and associated cost implications in clinical practice. Can J Gastroenterol. 1997;11(8):673-677. Not relevant to adherence. [pmid: 9459047].
Auricchio S, Greco L, Troncone R. Gluten-sensitive enteropathy in childhood. Pediatr Clin North Am. 1988;35(1):157-187. Not relevant to adherence. [pmid: 3277130].
Auricchio S, Troncone R. Effects of small amounts of gluten in the diet of coeliac patients. Panminerva Med. 1991;33(2):83-85. Not relevant to adherence. [pmid: 1923558].
Austin A S, Logan R F A, Thomason K, et al. Cigarette smoking and adult coeliac disease. Scand J Gastroenterol. 2002;37(8):978-982. Not relevant to adherence. [pmid: 12229976].
Bachle T, Ruhl U, Ott G, et al. Enteropathy-associated T-cell lymphoma, presenting as diet-refractory coeliac disease. Dtsch Med Wochenschr. 2001;126(5152):1460-1463. Not relevant to adherence. [pmid: 11753737].
Bai J C, Gonzalez D, Mautalen C, et al. Long-term effect of gluten restriction on bone mineral density of patients with coeliac disease. Aliment Pharmacol Ther. 1997;11(1):157-164. Not relevant to adherence. [pmid: 9042988].
Bai J, Moran C, Martinez C, et al. Celiac sprue after surgery of the upper gastrointestinal tract. Report of 10 patients with special attention to diagnosis, clinical behavior, and follow-up. J Clin Gastroenterol. 1991;13(5):521-524. Not relevant to adherence. [pmid: 1744387].
Bardella M T, Fraquelli M, Quatrini M, et al. Prevalence of hypertransaminasemia in adult celiac patients and effect of gluten-free diet. J Gastroenterol Hepatol. 1995;22(3):833-836. Not relevant to adherence.
Bardella M T, Fredella C, Prampolini L, et al. Body composition and dietary intakes in adult celiac disease patients consuming a strict gluten-free diet. Am J Clin Nutr. 2000;72(4):937-939. Not relevant to adherence. [pmid: 11010934].
Bardella M T, Molteni N, Prampolini L, et al. Need for follow up in coeliac disease. Arch Dis Child. 1994;70(3):211-213. Not relevant to adherence. [pmid: 8135565].
Bardella M T, Molteni N, Quatrini M, et al. Clinical, biochemical and histological abnormalities in adult celiac patients on gluten-free diet. Gastroenterol Clin Biol. 1985;9(11):787-789. Not relevant to adherence. [pmid: 4085741].
Barera G, Mora S, Brambilla P, et al. Body composition in children with celiac disease and the effects of a gluten-free diet: a prospective case-control study. Am J Clin Nutr. 2000;72(1):71-75. Not relevant to adherence. [pmid: 10871563].
Barna M, Pinter E. Anti-gliadin and anti-endomysium antibodies in children with celiac disease consuming a gluten free diet. Z Ernahrungswiss. 1998;37(Suppl 1):103-105. Monitoring not serology, EMA, tTG or biopsy based, or not promoting GFD adherence. [pmid: 9558738].
Bentley A C. A survey of celiac-sprue patients: effect of dietary restrictions on religious practices. J Gen Psychol. 1988;115(1):7-14. Not relevant to adherence. [pmid: 3351491].
Berger R, Schmidt G. Evaluation of six anti-gliadin antibody assays. J Immunol Methods. 1996;191(1):77-86. Not relevant to adherence. [pmid: 8642204].
Bhatia K P, Brown P, Gregory R, et al. Progressive myoclonic ataxia associated with coeliac disease: The myoclonus is of cortical origin, but the pathology is in the cerebellum. Brain Dev. 1995;118(5):1087-1093. Not relevant to adherence.
Biagi F, Corazza G R. A review on ulcerative jejunoileitis: LA JEJUNO-ILEITE ULCEREUSE: REVUE DE LA LITTERATURE. Acta Endoscopica. 2001;31(3):265-269. Not relevant to adherence.
Biagi F, Parnell N D, Ellis H J, et al. Endomysial antibody production is not related to histological damage after in vitro gluten challenge. Eur J Gastroenterol Hepatol. 2000;12(1):57-60. Not relevant to adherence. [pmid: 10656211].
Bjornsson E, Janson C, Plaschke P, et al. Prevalence of sensitization to food allergens in adult Swedes. Ann Allergy Asthma Immunol. 1996;77(4):327-332. Not relevant to adherence. [pmid: 8885811].
Blazer S, Naveh Y, Berant M, et al. Serum IgG antibodies to gliadin in children with celiac disease as measured by an immunofluorescence method. J Pediatr Gastroenterol Nutr. 1984;3(2):205-209. Not relevant to adherence. [pmid: 6368789].
Boersma B, Houwen R H J, Blum W F, et al. Catch-up growth and endocrine changes in childhood celiac disease. Endocrine changes during catch-up growth. Horm Res. 2002;58(Suppl 1):57-65. Not relevant to adherence. [pmid: 12373016].
Bonamico M, Mariani P, Mazzilli M C, et al. Frequency and clinical pattern of celiac disease among siblings of celiac children. J Pediatr Gastroenterol Nutr. 1996;23(2):159-163. Not relevant to adherence. [pmid: 8856583].
Bonamico M, Morellini M, Mariani P, et al. HLA antigens and antigliadin antibodies in coeliac disease. Dis Markers. 1991;9(6):313-317. Not relevant to adherence. [pmid: 1823310].
Booth I W. The nutritional consequences of gastrointestinal disease in adolescence. Acta Paediatrica Scandinavica.Supplement;. 1991;37391–102. Not relevant to adherence
Bottaro G, Failla P, Rotolo N, et al. Changes in coeliac disease behaviour over the years. Acta Paediatr. 1993;82(67):566-568. Not relevant to adherence. [pmid: 8338991].
Brink S J. Pediatric, adolescent, and young-adult nutrition issues in IDDM. Diabetes Care. 1988;11(2):192-200. Not relevant to adherence. [pmid: 3289868].
Broberg A, Engstrom I, Kalimo K, et al. Elimination diet in young children with atopic dermatitis. Acta Derm-Venereol. 1992;72(5):365-369. Not relevant to adherence. [pmid: 1361286].
Burrows R, Leiva L, Burgueno M, et al. Bone mineral density (BMD) in children with celiac disease (CD): Its relation to puberty and calcium intake. Nutr Res. 1999;19(4):493-499. Not relevant to adherence.
Butterfield J H, Murray J A. Eosinophilic gastroenteritis and gluten-sensitive enteropathy in the same patient. J Clin Gastroenterol. 2002;34(5):552-553. Not relevant to adherence. [pmid: 11960068].
Butterworth J R, Banfield L, Iqbal T H, et al. What factors influence compliance with a gluten-free diet? A comparison of white caucasian and South Asian coeliac patients. Gut. 2002;50(Suppl 2):A18. No correlations with other measures.
Byrne M F, Razak A R A, Leader M B, et al. Disabling osteomalacic myopathy as the only presenting feature of coeliac disease. Eur J Gastroenterol Hepatol. 2002;14(11):1271-1274. Not relevant to adherence. [pmid: 12439125].
Campbell J A, Molloy M K, Davidson A G F, et al. Dietary aspects from national survey of persons with celiac disease and dermatitis herpetiformis. J Can Diet Assoc. 1991;52(3):161-165. Not relevant to adherence.
Campbell J A. Diet therapy of celiac disease and dermatitis herpetiformis. World Rev Nutr Diet. 1987;51189–233. Not relevant to adherence
Campbell J A. Dietary management of celiac disease: variations in the gluten-free diet. J Can Diet Assoc. 1992;53(1):15-18. Not relevant to adherence.
Capristo E, Addolorato G, Mingrone G, et al. Changes in body composition, substrate oxidation, and resting metabolic rate in adult celiac disease patients after a 1-y gluten-free diet treatment. Am J Clin Nutr. 2000;72(1):76-81. Not relevant to adherence. [pmid: 10871564].
Capristo E, Mingrone G, Addolorato G, et al. Differences in metabolic variables between adult coeliac patients at diagnosis and patients on a gluten-free diet. Scand J Gastroenterol. 1997;32(12):1222-1229. Not relevant to adherence. [pmid: 9438320].
Cardenas A, Kelly C P. Celiac sprue. Semin Gastrointest Dis. 2002;13(4):232-244. Not relevant to adherence. [pmid: 12462708].
Carpino F, Ceccamea A, Magliocca F M, et al. Scanning electron microscopy of jejunal biopsies in patients with untreated and treated coeliac disease. Acta Paediatr Scand. 1985;74(5):775-781. Not relevant to adherence. [pmid: 4050426].
Carroccio A, Iacono G, Montalto G, et al. Pancreatic enzyme therapy in childhood celiac disease. A double-blind prospective randomized study. Dig Dis Sci. 1995;40(12):2555-2560. Not relevant to adherence. [pmid: 8536512].
Casellas F, De Torres I, Malagelada J-R. Follow-up of celiac disease with D-xylose breath test. Dig Dis Sci. 1996;41(10):2106-2111. Not relevant to adherence. [pmid: 8888728].
Cataldo F, Lio D, Marino V, et al. IgG(1) antiendomysium and IgG antitissue transglutaminase (anti-tTG) antibodies in coeliac patients with selective IgA deficiency. Working Groups on Celiac Disease of SIGEP and Club del Tenue. Gut. 2000;47(3):366-369. Not relevant to adherence. [pmid: 10940273]. [pmcid: 1728054].
Catassi C, Doloretta Macis M, Ratsch I-M, et al. The distribution of DQ genes in the Saharawi population provides only a partial explanation for the high celiac disease prevalence. Tissue Antigens. 2001;58(6):402-406. Not relevant to adherence. [pmid: 11929591].
Catassi C, Rossini M, Ratsch I M, et al. Dose dependent effects of protracted ingestion of small amounts of gliadin in coeliac disease children: a clinical and jejunal morphometric study. Gut. 1993;34(11):1515-1519. Not relevant to adherence. [pmid: 8244135]. [pmcid: 1374413].
Catassi C. Intestinal permeability tests: Research or diagnosis?. Pediatric Reviews and Communications. 1993;7(3):202-205. Not relevant to adherence.
Cellier C, Cervoni J P, Patey N, et al. Gluten-free diet induces regression of T-cell activation in the rectal mucosa of patients with celiac disease. Am J Gastroenterol. 1998;93(9):1527-1530. Not relevant to adherence. [pmid: 9732937].
Chapman B L, Henry K, Paice F, et al. Measuring the response of the jejunal mucosa in adult coeliac disease to treatment with a gluten-free diet. Gut. 1974;15(11):870-874. Not relevant to adherence. [pmid: 4455564]. [pmcid: 1413062].
Chartrand L J, Russo P A, Duhaime A G, et al. Wheat starch intolerance in patients with celiac disease. J Am Diet Assoc. 1997;97(6):612-618. Not relevant to adherence. [pmid: 9183321].
Ciacci C, Cirillo M, Mellone M, et al. Hypocalciuria in overt and subclinical celiac disease. Am J Gastroenterol. 1995;90(9):1480-1484. Not relevant to adherence. [pmid: 7661174].
Ciacci C, De Rosa A, de Michele G, et al. Sexual behaviour in untreated and treated coeliac patients. Eur J Gastroenterol Hepatol. 1998;10(8):649-651. Not relevant to adherence. [pmid: 9744692].
Ciacci C, Di Vizio D, Seth R, et al. Selective reduction of intestinal trefoil factor in untreated coeliac disease. Clin Exp Immunol. 2002;130(3):526-531. Not relevant to adherence. [pmid: 12452845]. [pmcid: 1906543].
Ciacci C, Iavarone A, Mazzacca G, et al. Depressive symptoms in adult coeliac disease. Scand J Gastroenterol. 1998;33(3):247-250. Not relevant to adherence. [pmid: 9548616].
Ciacci C, Maurelli L, Klain M, et al. Effects of dietary treatment on bone mineral density in adults with celiac disease: factors predicting response. Am J Gastroenterol. 1997;92(6):992-996. Not relevant to adherence. [pmid: 9177517].
Ciacci Carolina, Iavarone Alessandro, Siniscalchi Monica, et al. Psychological dimensions of celiac disease: toward an integrated approach. Dig Dis Sci. 2002;47(9):2082-2087. Not relevant to adherence. [pmid: 12353859].
Ciampolini M, Bini S. Serum lipids in celiac children. J Pediatr Gastroenterol Nutr. 1991;12(4):459-460. No correlations with other measures. [pmid: 1865279].
Ciclitira P J, Ellis H J, Evans D J, et al. A radioimmunoassay for wheat gliadin to assess the suitability of gluten free foods for patients with coeliac disease. Clin Exp Immunol. 1985;59(3):703-708. Not relevant to adherence. [pmid: 3987095]. [pmcid: 1576931].
Ciclitira P J. Recent advances in coeliac disease. Clin Med. 2003;3(2):166-169. Not relevant to adherence. [pmid: 12737376].
Cinquetti M, Trabucchi C, Menegazzi N, et al. Psychological problems connected to the dietary restrictions in the adolescent with coeliac disease. La Pediatria Medica E Chirurgica - Medical and Surgical Pediatrics. 1999;21(6):279-283. Not relevant to adherence. [pmid: 11293149].
Cocchi Renato. Toilet habits in drugs treated downs: A survey on 209 subjects. Italian Journal of Intellective Impairment. 1997;10(1):13-17. Not relevant to adherence.
Colaco J, Egan-Mitchell B, Stevens F M, et al. Compliance with gluten free diet in coeliac disease. Arch Dis Child. 1987;62(7):706-708. Not relevant to adherence. [pmid: 3632017].
Collin P, Hallstrom O, Maki M, et al. Atypical coeliac disease found with serologic screening. Scand J Gastroenterol. 1990;25(3):245-250. Not relevant to adherence. [pmid: 2320942].
Collin P, Pirttilae T, Nurmikko T, et al. Celiac Disease, Brain Atrophy, and Dementia. Neurology. 1991;41(3):372-375. Not relevant to adherence. [pmid: 2006004].
Collin P, Reunala T. Recognition and management of the cutaneous manifestations of celiac disease: A guide for dermatologists. Am J Clin Dermatol. 2003;4(1):13-20. Not relevant to adherence. [pmid: 12477369].
Collins B J, Bell P M, Boyd S, et al. Endocrine and exocrine pancreatic function in treated coeliac disease. Pancreas. 1986;1(2):143-147. Not relevant to adherence. [pmid: 3554222].
Collins B J, Bell P M, Thomson J M, et al. Dietary history and nutritional state in treated coeliac patients. J R Soc Med. 1986;79(4):206-209. Not relevant to adherence. [pmid: 3701766]. [pmcid: 1290275].
Congdon P, Mason M K, Smith S, et al. Small-bowel mucosa in asymptomatic children with celiac disease. Mucosal changes with gluten-free diets. Am J Dis Child. 1981;135(2):118-121. Not relevant to adherence. [pmid: 7468543].
Corazza G R, Di Sario A, Sacco G, et al. Subclinical coeliac disease: an anthropometric assessment. J Intern Med. 1994;236(2):183-187. No monitoring measure of interest. [pmid: 8046318].
Corazza G R, Di Stefano M, Jorizzo R A, et al. Propeptide of type I procollagen is predictive of posttreatment bone mass gain in adult celiac disease. Gastroenterology. 1997;113(1):67-71. Not relevant to adherence. [pmid: 9207263].
Corrao G, Corazza G R, Bagnardi V, et al. Mortality in patients with coeliac disease and their relatives: a cohort study. Lancet. 2001;358(9279):356-361. Not relevant to adherence. [pmid: 11502314].
Corvaglia L, Catamo R, Pepe G, et al. Depression in adult untreated celiac subjects: Diagnosis by the pediatrician. Am J Gastroenterol. 1999;94(3):839-843. Not relevant to adherence. [pmid: 10086676].
Crofton R W, Glover S C, Ewen S W, et al. Zinc absorption in celiac disease and dermatitis herpetiformis: a test of small intestinal function. Am J Clin Nutr. 1983;38(5):706-712. No monitoring measure of interest. [pmid: 6637862].
Cronin C C, Feighery A, Ferriss J B, et al. High prevalence of celiac disease among patients with insulin-dependent (type I) diabetes mellitus. Am J Gastroenterol. 1997;92(12):2210-2212. Not relevant to adherence. [pmid: 9399754].
Cronin Cornelius C, Shanahan Fergus. Exploring the iceberg--the spectrum of celiac disease. Am J Gastroenterol. 2003;98(3):518-520. Not relevant to adherence. [pmid: 12650779].
Cummings A G, Thompson F M, Butler R N, et al. Improvement in intestinal permeability precedes morphometric recovery of the small intestine in coeliac disease. Clinical Science (London, England - 1979). 2001;100(4):379-386. Not relevant to adherence. [pmid: 11256975].
Cuoco L, Cammarota G, Tursi A, et al. Disappearance of gastric mucosa-associated lymphoid tissue in coeliac patients after gluten withdrawal. Scand J Gastroenterol. 1998;33(4):401-405. Not relevant to adherence. [pmid: 9605262].
Cuomo A, Romano M, Rocco A, et al. Reflux oesophagitis in adult coeliac disease: beneficial effect of a gluten free diet. Gut. 2003;52(4):514-517. Not relevant to adherence. [pmid: 12631661]. [pmcid: 1773586].
Curione M, Barbato M, Viola F, et al. Idiopathic dilated cardiomyopathy associated with coeliac disease: The effect of a gluten-free diet on cardiac performance. Dig Dis Sci. 2002;34(12):866-869. Not relevant to adherence.
Dahele A V, Aldhous M C, Humphreys K, et al. Serum IgA tissue transglutaminase antibodies in coeliac disease and other gastrointestinal diseases. Q J Med. 2001;94(4):195-205. Not relevant to adherence.
Damen G M, Boersma B, Wit J M, et al. Catch-up growth in 60 children with celiac disease. J Pediatr Gastroenterol Nutr. 1994;19(4):394-400. Not relevant to adherence. [pmid: 7876992].
Damoiseaux J G M C, Tervaert J W C. Celiac disease: the role of (auto)antibody detection in diagnosis and follow-up. Neth J Med. 2002;60(7):303-304. Review article. [pmid: 12430584].
Daniels D E, Rene A A, Daniels V R. Race: an Explanation of Patient Compliance: Fact or Fiction?. J Natl Med Assoc. 1994;86(1):20-25. Not relevant to adherence. [pmid: 8151719].
Davis M K. Breastfeeding and chronic disease in childhood and adolescence. Pediatr Clin North Am. 2001;48(1):125-141. Not relevant to adherence. [pmid: 11236720].
De Lorenzo A, Di Campli C, Andreoli A, et al. Assessment of body composition by bioelectrical impedance in adolescent patients with celiac disease. Am J Gastroenterol. 1999;94(10):2951-2955. Not relevant to adherence. [pmid: 10520850].
de Vries T W, Wierdsma N, van Ede J, et al. Dieting in children referred to the paediatric outpatient clinic. Eur J Pediatr. 2001;160(10):595-598. Not relevant to adherence. [pmid: 11686502].
Denman A M. Nature and diagnosis of food allergy. Proc Nutr Soc. 1979;38(3):391-402. Not relevant to adherence. [pmid: 161023].
Devine P L, Birrell G W, Golder J P, et al. Screening and monitoring coeliac disease: multicentre trial of a new serum antibody test kit. Dis Markers. 1994;12(1):71-80. Not relevant to adherence. [pmid: 7842632].
Di Sabatino A, Bertrandi E, Casadei Maldini M, et al. Phenotyping of peripheral blood lymphocytes in adult coeliac disease. Immunology. 1998;95(4):572-576. Not relevant to adherence. [pmid: 9893047]. [pmcid: 1364354].
Di Stefano M, Veneto G, Corrao G, et al. Role of lifestyle factors in the pathogenesis of osteopenia in adult coeliac disease: A multivariate analysis. Eur J Gastroenterol Hepatol. 2000;12(11):1195-1199. Not relevant to adherence. [pmid: 11111775].
Diamanti A, Maino C, Niveloni S, et al. Characterization of gastric mucosal lesions in patients with celiac disease: a prospective controlled study. Am J Gastroenterol. 1999;94(5):1313-1319. Not relevant to adherence. [pmid: 10235212].
Dickey W, Bodkin S. Prospective study of body mass index in patients with coeliac disease. BMJ. 1998;317(7168):1290. Not relevant to adherence. [pmid: 9804717]. [pmcid: 28710].
Dimatteo M R, Giordani P J, Lepper H S, et al. Patient Adherence and Medical Treatment Outcomes - a Meta- Analysis. Med Care. 2002;40(9):794-811. Not relevant to adherence. [pmid: 12218770].
Dimatteo M R, Lepper H S, Croghan T W. Depression Is a Risk Factor for Noncompliance With Medical Treatment - Meta-Analysis of the Effects of Anxiety and Depression on Patient Adherence. Arch Intern Med. 2000;160(14):2101-2107. Not relevant to adherence. [pmid: 10904452].
Dinari G, Rosenbach Y, Marcus H, et al. IgA antigliadin antibodies in childhood celiac disease. Isr J Med Sci. 1988;24(6):286-290. Not relevant to adherence. [pmid: 3403224].
Dissanayake A S, Truelove S C, Whitehead R. Jejunal mucosal recovery in coeliac disease in relation to the degree of adherence to a gluten-free diet. Q J Med. 1974;43(170):161-185. Not relevant to adherence. [pmid: 4604652].
Dohan F C. Is celiac disease a clue to the pathogenesis of schizophrenia?. Ment Hyg. 1969;53(4):525-529. Not relevant to adherence. [pmid: 5344577].
Donat Aliaga E, Polo Miquel B, Ribes-Koninckx C. Serological markers of celiac disease. Acta Pediatr Esp. 2003;61(1):24-32. Not relevant to adherence.
Dubel L, Absalon Y B, Baudon J J, et al. Screening of coeliac disease: Optimal technique and serological marker. Ann Biol Clin (Paris). 1996;54(7):303-306. Not relevant to adherence. [pmid: 8952728].
Elsborg L, Mosbech J. Sprue: a follow-up study of an old series. Dan Med Bull. 1978;25(5):205-206. Not relevant to adherence. [pmid: 699635].
Erdman John W. Factors that limit or enhance bioavailability of minerals from food. Nutrition & the Md. 1983;9(2):1-2. Not relevant to adherence.
Falth-Magnusson K, Franzen L, Jansson G, et al. Infant feeding history shows distinct differences between Swedish celiac and reference children. Pediatric Allergy and Immunology - Official Publication of the European Society of Pediatric Allergy and Immunology. 1996;7(1):1-5. Not relevant to adherence. [pmid: 8792377].
Falzon L. Topic: Gluten-free diet of coeliac disease. J Clin Excellence. 2001;3(4):209-211. Not relevant to adherence.
Fasano A, Catassi C. Current approaches to diagnosis and treatment of celiac disease: an evolving spectrum. Gastroenterology. 2001;120(3):636-651. Not relevant to adherence. [pmid: 11179241].
Fasano Alessio. Celiac disease--how to handle a clinical chameleon. N Engl J Med. 2003;348(25):2568-2570. Not relevant to adherence. [pmid: 12815143].
Faulkner-Hogg K B, Selby W S, Loblay R H. Dietary analysis in symptomatic patients with coeliac disease on a gluten-free diet: the role of trace amounts of gluten and non-gluten food intolerances. Scand J Gastroenterol. 1999;34(8):784-789. Not relevant to adherence. [pmid: 10522611].
Feighery C F. Coeliac disease: How much of what is toxic to whom?. Gut. 1998;43(2):164-165. Not relevant to adherence. [pmid: 10189837]. [pmcid: 1727227].
Ferfoglia G, Pulitano R, Sategna-Guidetti C. Do dietary antibodies still play a role in the diagnosis and follow-up of coeliac disease? A comparison among different serological tests. Panminerva Med. 1995;37(2):55-59. Not relevant to adherence. [pmid: 8637769].
Ferguson A, Denton-Miller P, Lai C L. Coeliac disease--objectives of life-long follow-up. Health Bull (Edinb). 1977;35(2):78-80. Not relevant to adherence. [pmid: 404272].
Ferguson A. Symptoms and manifestations of food allergy, with particular relevance to the gut. Environ Toxicol Pharmacol. 1997;4(12):33-38. Not relevant to adherence.
Fernandez-Calle P, Codoceo R, Polanco I, et al. Is an intestinal permeability test a valid marker for slight dietary transgressions in adolescents with coeliac disease?. Gut. 1993;34(6):774-777. No monitoring measure of interest. [pmid: 8314509]. [pmcid: 1374260].
Fine K D, Meyer R L, Lee E L. The prevalence and causes of chronic diarrhea in patients with celiac sprue treated with a gluten-free diet. Gastroenterology. 1997;112(6):1830-1838. Not relevant to adherence. [pmid: 9178673].
Finkel M, Gelb A M, Cohen N, et al. Long-term follow-up study in idiopathic steatorrhea. Am J Gastroenterol. 1967;47(1):35-40. Not relevant to adherence. [pmid: 6017662].
Finn R. Food allergy - fact or fiction: A review. J R Soc Med. 1992;85(9):560-564. Not relevant to adherence. [pmid: 1433127]. [pmcid: 1293647].
Flanagan D A, Wagner H L. Expressed Emotion and Panic^Fear in the Prediction of Diet Treatment Compliance. Br J Clin Psychol. 1991;30(3):231-240. Not relevant to adherence. [pmid: 1933042].
Fois A, Vascotto M, Di Bartolo R M, et al. Celiac disease and epilepsy in pediatric patients. Child's Nerv Syst. 1994;10(7):450-454. Not relevant to adherence. [pmid: 7842435].
Fox L A. Diabetes therapy in children: Setting age-appropriate goals. Drug Benefit Trends. 2002;14(Suppl D):30-3544. Not relevant to adherence.
Francesco Stefanini G, Resta F, Marsigli L, et al. Prurigo nodularis (Hyde's prurigo) disclosing celiac disease. Hepatogastroenterology. 1999;46(28):2281-2284. Not relevant to adherence. [pmid: 10521982].
Francis Dorothy E M. Inborn errors of metabolism: The need for sugar. J Hum Nutr. 1979;33(2):146-154. Not relevant to adherence. [pmid: 438511].
Freeman H J. Free perforation due to intestinal lymphoma in biopsy-defined or suspected celiac disease. J Clin Gastroenterol. 2003;37(4):299-302. Not relevant to adherence. [pmid: 14506386].
Fried M W. Side effects of therapy of hepatitis C and their management. J Gastroenterol Hepatol. 2002;36(5 I):S237-S244. Not relevant to adherence. [pmid: 11982722].
Friis S U. Enzyme-linked immunosorbent assay for quantitation of cereal proteins toxic in coeliac disease. Clin Chim Acta. 1988;178(3):261-270. Not relevant to adherence. [pmid: 3240601].
Fry L, Seah P P, Riches D J, et al. Clearance of skin lesions in dermatitis herpetiformis after gluten withdrawal. Lancet. 1973;1(7798):288-291. Not relevant to adherence. [pmid: 4119171].
Fuhrmann A, Kuhl J. Maintaining a Healthy Diet: Effects of Personality and Self-Reward Versus Self-Punishment on Commitment to and Enactment of Self-Chosen and Assigned Goals. Psychol Health. 1998;13(4):651-686. Not relevant to adherence.
Gabel L L, Latanick M R. Nutrition-related prevention: An interdisciplinary strategy. J Fam Pract. 1993;37(4):396-398. Not relevant to adherence. [pmid: 8409894].
Galli-Tsinopoulou A, Nousia-Arvanitakis S, Dracoulacos D, et al. Autoantibodies predicting diabetes mellitus type I in celiac disease. Horm Res. 1999;52(3):119-124. Not relevant to adherence. [pmid: 10725775].
Garioch J J, Lewis H M, Sargent S A, et al. 25 years' experience of a gluten-free diet in the treatment of dermatitis herpetiformis. Br J Dermatol. 1994;131(4):541-545. Not relevant to adherence. [pmid: 7947207].
Gawkrodger D J, Vestey J P, O'Mahony S, et al. Dermatitis herpetiformis and established coeliac disease. Br J Dermatol. 1993;129(6):694-695. Not relevant to adherence. [pmid: 8286252].
Gemme G, Vignolo M, Naselli A, et al. Linear growth and skeletal maturation in subjects with treated celiac disease. J Pediatr Gastroenterol Nutr. 1999;29(3):339-342. Not relevant to adherence. [pmid: 10468002].
Gillberg R, Ahren C. Coeliac disease diagnosed by means of duodenoscopy and endoscopic duodenal biopsy. Scand J Gastroenterol. 1977;12(8):911-916. Not relevant to adherence. [pmid: 605350].
Gillett H R, Arnott I D R, McIntyre M, et al. Successful infliximab treatment for steroid-refractory celiac disease: A case report. Gastroenterology. 2002;122(3):800-805. Not relevant to adherence. [pmid: 11875014].
Gillett P M, Gillett H R, Israel D M, et al. High prevalence of celaic disease in patients with type 1 diabetes detected by antibodies to endomysium and tissue transglutaminase. Can J Gastroenterol. 2001;15(5):297-301. Not relevant to adherence. [pmid: 11381296].
Giomi B, Cardinali C, Caproni M, et al. Immunological markers in dermatitis herpetiformis: Anti-endomysium and anti-transglutaminase in association with increased myeloperoxidase and eosinophil cationic protein serum levels. Int J Med Biol Environ. 2001;29(2):149-153. Not relevant to adherence.
Gonczi J, Skerritt J H, Mitchell J D. A reliable screening test for coeliac disease: enzyme-linked immunosorbent assay to detect anti-gliadin antibodies in serum. Aust N Z J Med. 1991;21(5):723-731. Not relevant to adherence. [pmid: 1759921].
Greco L, Mayer M, Ciccarelli G, et al. Compliance to a gluten-free diet in adolescents, or “what do 300 coeliac adolescents eat every day?”. Ital J Gastroenterol Hepatol. 1997;29(4):305-310. Not relevant to adherence. [pmid: 9476181].
Greco L, Mayer M, Grimaldi M, et al. The Effects of early feeding on the onset of Symptoms in celiac disease. J Pediatr Gastroenterol Nutr. 1985;4(1):52-59. Not relevant to adherence. [pmid: 3981369].
Greco L, Percopo S. The coeliac disease task force “ Free from Gluten,”“Improved knowledge to cure coeliac disease”. Acta Paediatrica.Supplement. 1996;4225–28. Not relevant to adherence
Greco L, Tipo V, Di Donato F, et al. Pulsatile growth pattern during catch-up growth in childhood coeliac disease. Acta Paediatr. 1994;83(7):724-729. Not relevant to adherence. [pmid: 7949802].
Green P H R, Fleischauer A T, Bhagat G, et al. Risk of malignancy in patients with celiac disease. Am J Med. 2003;115(3):191-195. Not relevant to adherence. [pmid: 12935825].
Green P H R, Stavropoulos S N, Panagi S G, et al. Characteristics of adult celiac disease in the USA: results of a national survey. Am J Gastroenterol. 2001;96(1):126-131. Not relevant to adherence. [pmid: 11197241].
Grefte J M, Bouman J G, Grond J, et al. Slow and incomplete histological and functional recovery in adult gluten sensitive enteropathy. J Clin Pathol. 1988;41(8):886-891. Not relevant to adherence. [pmid: 3170777]. [pmcid: 1141622].
Grehn S, Fridell K, Lilliecreutz M, et al. Dietary habits of Swedish adult coeliac patients treated by a gluten-free diet for 10 years. Scand J Nutr Naringsforsk. 2001;45(4):178-182. Not relevant to adherence.
Gryboski J. False security of a gluten-free diet. Am J Dis Child. 1981;135(2):110-111. Not relevant to adherence. [pmid: 7468541].
Guandalini S, Ventura A, Ansaldi N, et al. Diagnosis of coeliac disease: time for a change?. Arch Dis Child. 1989;64(9):1320-1325. Not relevant to adherence. [pmid: 2817956].
Guandalini S. Celiac disease in the new world. J Pediatr Gastroenterol Nutr. 2000;31(4):362-364. Not relevant to adherence. [pmid: 11045848].
Hadjivassiliou M, Davies-Jones G A B, Sanders D S, et al. Dietary treatment of gluten ataxia. J Neurol Neurosurg Psychiatry. 2003;74(9):1221-1224. Not relevant to adherence. [pmid: 12933922].
Hallert C, Granno C, Grant C, et al. Quality of life of adult coeliac patients treated for 10 years. Scand J Gastroenterol. 1998;33(9):933-938. Not relevant to adherence. [pmid: 9759948].
Hallert C, Granno C, Hulten S, et al. Living with coeliac disease: controlled study of the burden of illness. Scand J Gastroenterol. 2002;37(1):39-42. Not relevant to adherence. [pmid: 11843033].
Hallert C, Grant C, Grehn S, et al. Evidence of poor vitamin status in coeliac patients on a gluten-free diet for 10 years. Aliment Pharmacol Ther. 2002;16(7):1333-1339. Not relevant to adherence. [pmid: 12144584].
Hallert C, Lohiniemi S. Quality of life of celiac patients living on a gluten-free diet. Nutrition. 1999;15(10):795-797. Not relevant to adherence. [pmid: 10501298].
Hallert C, Tobiasson P, Walan A. Serum folate determinations in tracing adult coeliacs. Scand J Gastroenterol. 1981;16(2):263-267. Not relevant to adherence. [pmid: 7313538].
Hallstrom O, Reunala T. IgA class reticulin antibodies in dermatitis herpetiformis: a good indicator of jejunal damage. Acta Derm Venereol. 1985;65(4):330-332. Not relevant to adherence. [pmid: 2413688].
Hamilton J R, McNeill L K. Childhood celiac disease: response of treated patients to a small uniform daily dose of wheat gluten. Eur J Pediatr. 1972;81(5):885-893. Not relevant to adherence.
Hankey G L, Holmes G K. Coeliac disease in the elderly. Gut. 1994;35(1):65-67. Not relevant to adherence. [pmid: 8307452]. [pmcid: 1374634].
Hansson T, Dahlbom I, Rogberg S, et al. Recombinant human tissue transglutaminase for diagnosis and follow-up of childhood coeliac disease. Pediatr Res. 2002;51(6):700-705. Not relevant to adherence. [pmid: 12032264].
Hansson T, Dannaeus A, Kraaz W, et al. Production of antibodies to gliadin by peripheral blood lymphocytes in children with celiac disease: the use of an enzyme-linked immunospot technique for screening and follow-up. Pediatr Res. 1997;41(4 Pt 1):554-559. Not relevant to adherence. [pmid: 9098859].
Harris O D, Warner M, Cooke W T. Serum alkaline phosphatase in adult coeliac disease. Gut. 1969;10(11):951. Not relevant to adherence. [pmid: 5358593].
Hawkes N D, Swift G L, Smith P M, et al. Incidence and presentation of coeliac disease in South Glamorgan. Eur J Gastroenterol Hepatol. 2000;12(3):345-349. Not relevant to adherence. [pmid: 10750656].
Henry C L. Patients' view of a gluten-free diet. J Hum Nutr. 1980;34(1):50-51. Not relevant to adherence. [pmid: 7358972].
Hernandez M A, Colina G, Ortigosa L. Epilepsy, cerebral calcifications and clinical or subclinical coeliac disease. Course and follow up with gluten-free diet. Seizure - the Journal of the British Epilepsy Association. 1998;7(1):49-54. Not relevant to adherence. [pmid: 9548226].
Hetzel P A S, Labrooy J T, Bellon M. The sup 5sup 1Cr EDTA absorption test in coeliac patients treated with a gluten free diet. Ircs Med Sci. 1986;14(12):1183-1184. Not relevant to adherence.
Hill P G, Thompson S P, Holmes G K. IgA anti-gliadin antibodies in adult celiac disease. Clin Chem. 1991;37(5):647-650. Not relevant to adherence. [pmid: 2032317].
Hjelt K, Krasilnikoff P A. The impact of gluten on haematological status, dietary intakes of haemopoietic nutrients and vitamin B12 and folic acid absorption in children with coeliac disease. Acta Paediatr Scand. 1990;79(10):911-919. Not relevant to adherence. [pmid: 2267921].
Holmes G K T. Coeliac disease and malignancy. Dig Dis Sci. 2002;34(3):229-237. Not relevant to adherence.
Holmes G K, Asquith P, Stokes P L, et al. Cellular infiltrate of jejunal biopsies in adult coeliac disease (ACD) in relation to gluten withdrawal. Gut. 1973;14(5):429. Not relevant to adherence. [pmid: 4743492].
Holmes G K, Asquith P, Stokes P L, et al. Cellular infiltrate of jejunal biopsies in adult coeliac disease in relation to gluten withdrawal. Gut. 1974;15(4):278-283. Not relevant to adherence. [pmid: 4834552]. [pmcid: 1412953].
Holmes G K, Prior P, Lane M R, et al. Malignancy in coeliac disease--effect of a gluten free diet. Gut. 1989;30(3):333-338. Not relevant to adherence. [pmid: 2707633]. [pmcid: 1378455].
Holmes G K, Stokes P L, Sorahan T M, et al. Coeliac disease, gluten-free diet, and malignancy. Gut. 1976;17(8):612-619. Not relevant to adherence. [pmid: 789184]. [pmcid: 1411326].
Holmes G K. Non-malignant complications of coeliac disease. Acta Paediatrica.Supplement. 1996;41268–75. Not relevant to adherence
Horvath K, Horn G. Tardyferon therapy in hyposiderosis of infancy and childhood. Ther Hung. 1992;40(1):40-43. Not relevant to adherence. [pmid: 1585284].
Horvath-Stolarczyk A, Sidor K, Dziechciarz P, et al. Assessment of emotional status, selected personality traits and depression in young adults with celiac disease. Pediatr Wspolczesna. 2002;4(3):241-246. Not relevant to adherence.
Huff C. Celiac disease: helping families adapt. Gastroenterology Nursing - the Official Journal of the Society of Gastroenterology Nurses and Associates. 1997;20(3):79-81. Not relevant to adherence. [pmid: 9238934].
Hussain G, Ali S, Iqbal M M, et al. Study of coeliac disease in children. J Coll Phys Surg Pak. 1999;9(2):81-84. Not relevant to adherence.
Ibbotson M. Gluten-free diets--helping patients to cope. Prof Nurse. 1986;1(8):219-220. Not relevant to adherence. [pmid: 3643595].
Ibbotson M. Living with a gluten-free diet. Prof Nurse. 1986;1(8):221-222. Not relevant to adherence. [pmid: 3643595].
Iliffe G D, Owen D A. An association between primary biliary cirrhosis and jejunal villous atrophy resembling celiac disease. Dig Dis Sci. 1979;24(10):802-806. Not relevant to adherence. [pmid: 487918].
Iovino P, Ciacci C, Sabbatini F, et al. Esophageal impairment in adult celiac disease with steatorrhea. Am J Gastroenterol. 1998;93(8):1243-1249. Not relevant to adherence. [pmid: 9707045].
Ivarsson A, Persson L A, Hernell O. Does breast-feeding affect the risk for coeliac disease?. Adv Exp Med Biol. 2000;478139–149. Not relevant to adherence
Ivarsson A, Persson L A, Nystrom L, et al. The Swedish coeliac disease epidemic with a prevailing twofold higher risk in girls compared to boys may reflect gender specific risk factors. Eur J Epidemiol. 2003;18(7):677-684. Not relevant to adherence. [pmid: 12952142].
Janatuinen E K, Kemppainen T A, Julkunen R J K, et al. No harm from five year ingestion of oats in coeliac disease. Gut. 2002;50(3):332-335. Not relevant to adherence. [pmid: 11839710]. [pmcid: 1773136].
Janatuinen E K, Kemppainen T A, Pikkarainen P H, et al. Lack of cellular and humoral immunological responses to oats in adults with coeliac disease. Gut. 2000;46(3):327-331. Not relevant to adherence. [pmid: 10673292]. [pmcid: 1727854].
Janatuinen E K, Pikkarainen P H, Kemppainen T A, et al. A comparison of diets with and without oats in adults with celiac disease. N Engl J Med. 1995;333(16):1033-1037. Not relevant to adherence. [pmid: 7675045].
Jansson U H, Gudjonsdottir A H, Ryd W, et al. Two different doses of gluten show a dose-dependent response of enteropathy but not of serological markers during gluten challenge in children with coeliac disease. Acta Paediatr. 2001;90(3):255-259. Not relevant to adherence. [pmid: 11332163].
Jarvinen T T, Kaukinen K, Laurila K, et al. Intraepithelial lymphocytes in celiac disease. Am J Gastroenterol. 2003;98(6):1332-1337. Not relevant to adherence. [pmid: 12818278].
Jessernigg G, Goriup U, Deutsch J, et al. The importance of antibodies in the guidance of coeliac patients. Jpgn. 2000;31(Suppl 2):S65-S66. No correlations with other measures.
Jewell D P. Celiac disease. Can J Gastroenterol. 2000;14(8):665-666. Not relevant to adherence. [pmid: 11185528].
Jodl J, Stepan J, Lojda Z. Diagnostic significance of determination of serum alkaline phosphatase intestinal isoenzyme activity in coeliac sprue in childhood. Acta Universitatis Carolinae.Medica.Monographia 1977;(78 Pt 2):65–70. Not relevant to adherence
Johnston S D, Peter Watson R G, McMillan S A. Soda bread provocation test for subjects with transient serology for coeliac disease 3 years after a population screening survey. Eur J Gastroenterol Hepatol. 2000;12(9):1013-1015. Not relevant to adherence. [pmid: 11007138].
Johnston S D, Smye M, Watson R P. Intestinal permeability tests in coeliac disease. Clin Lab. 2001;47(34):143-150. Not relevant to adherence. [pmid: 11294577].
Johnston S D, Watson R G, McMillan S A, et al. Coeliac disease detected by screening is not silent--simply unrecognized. Q J Med. 1998;91(12):853-860. Not relevant to adherence.
Johnston S D, Watson R G, Middleton D, et al. Genetic, morphometric and immunohistochemical markers of latent coeliac disease. Eur J Gastroenterol Hepatol. 1999;11(11):1283-1288. Not relevant to adherence. [pmid: 10563541].
Jones P E, Peters T J. DNA synthesis by jejunal mucosa in responsive and non-responsive coeliac disease. Br Med J. 1977;1(6069):1130-1131. Not relevant to adherence. [pmid: 861498]. [pmcid: 1606647].
Joshi Preeti, Mofidi Shideh, Sicherer Scott H. Interpretation of commercial food ingredient labels by parents of food-allergic children. J Allergy Clin Immunol. 2002;109(6):1019-1021. Not relevant to adherence. [pmid: 12063534].
Junqueira JC, Calcado AC, Percope S. Compliance of coeliac pediatric patients in Rio De Janeiro Brazil. J Pediatr Gastroenterol Nutr 2000; 31(Suppl 2). No correlations with other measures
Juto P, Fredrikzon B, Hernell O. Gliadin-specific serum immunoglobulins A, E, G, and M in childhood: Relation of small intestine mucosal morphology. J Pediatr Gastroenterol Nutr. 1985;4(5):723-729. Monitoring not serology, EMA, tTG or biopsy based, or not promoting GFD adherence. [pmid: 4045630].
Kalayci A G, Kansu A, Girgin N, et al. Bone mineral density and importance of a gluten-free diet in patients with celiac disease in childhood. Pediatrics. 2001;108(5):E89. Not relevant to adherence. [pmid: 11694673].
Kalra K K, Jain N, Mittal S K. Management of celiac disease. Indian J Pediatr. 1999;66(1 Suppl):S32-S36. Not relevant to adherence. [pmid: 11132466].
Kapuscinska A, Zalewski T, Chorzelski T P, et al. Disease specificity and dynamics of changes in IgA class anti-endomysial antibodies in celiac disease. J Pediatr Gastroenterol Nutr. 1987;6(4):529-534. Not relevant to adherence. [pmid: 3323442].
Kastrup W, Andersson H, Gillberg R, et al. Influence of gluten-free diet on the gastric condition in dermatitis herpetiformis. Scand J Gastroenterol. 1985;20(1):39-45. Not relevant to adherence. [pmid: 3992162].
Katz K D. Celiac Disease - Current Clinical Considerations in Treatment and Avoidance of Nutritional Deficiencies. Today's Ther Trends. 2003;21(4):379-389. Not relevant to adherence.
Kaukinen K, Collin P, Holm K, et al. Wheat starch-containing gluten-free flour products in the treatment of coeliac disease and dermatitis herpetiformis. A long-term follow-up study. Scand J Gastroenterol. 1999;34(2):163-169. Not relevant to adherence. [pmid: 10192194].
Kaukinen K, Salmi J, Lahtela J, et al. No effect of gluten-free diet on the metabolic control of type 1 diabetes in patients with diabetes and celiac disease. Diabetes Care. 1999;22(10):1747-1748. Not relevant to adherence. [pmid: 10526749].
Kelly C P, Feighery C F, Gallagher R B, et al. Msucosal and systemic IgA anti-gliadin antibody in celiac disease. Contrasting patterns of response in serum, saliva, and intestinal secretions. Dig Dis Sci. 1991;36(6):743-751. Not relevant to adherence. [pmid: 2032515].
Kemppainen T A, Kosma V M, Janatuinen E K, et al. Nutritional status of newly diagnosed celiac disease patients before and after the institution of a celiac disease diet--association with the grade of mucosal villous atrophy. Am J Clin Nutr. 1998;67(3):482-487. Not relevant to adherence. [pmid: 9497194].
Kemppainen T, Kroger H, Janatuinen E, et al. Bone recovery after a gluten-free diet: a 5-year follow-up study. Bone. 1999;25(3):355-360. Not relevant to adherence. [pmid: 10495140].
Kemppainen T, Kroger H, Janatuinen E, et al. Osteoporosis in adult patients with celiac disease. Bone. 1999;24(3):249-255. Not relevant to adherence. [pmid: 10495140].
Kemppainen T, Uusitupa M, Janatuinen E, et al. Intakes of nutrients and nutritional status in coeliac patients. Scand J Gastroenterol. 1995;30(6):575-579. Not relevant to adherence. [pmid: 7569766].
Kennedy N P, Feighery C. Clinical features of coeliac disease today. Biomed Pharmacother. 2000;54(7):373-380. Not relevant to adherence. [pmid: 10989976].
Khoshoo V, Bhan M K, Puri S, et al. Serum anti-gliadin antibody profile in childhood protracted diarrhoea due to coeliac disease and other causes in a developing country. Scand J Gastroenterol. 1989;24(10):1212-1216. Not relevant to adherence. [pmid: 2602903].
Khuffash F A, Barakat M H, Shaltout A A, et al. Coeliac disease among children in Kuwait: difficulties in diagnosis and management. Gut. 1987;28(12):1595-1599. Not relevant to adherence. [pmid: 3428686]. [pmcid: 1433935].
Kieffer M, Barnetson R S, Blackwell J N. Sequential studies of gliadin antibodies in patients with dermatitis herpetiformis. Arch Dermatol Res. 1984;276(2):74-77. No correlations with other measures. [pmid: 6721574].
Kieffer M. Serum antibodies to gliadin and other cereal proteins in patients with coeliac disease and dermatitis herpetiformis. Dan Med Bull. 1985;32(5):251-262. Not relevant to adherence. [pmid: 4053695].
Kieslich M, Errazuriz G, Posslt H G, et al. Brain white-matter lesions in celiac disease: a prospective study of 75 diet-treated patients. Pediatrics. 2001;108(2):E21. Not relevant to adherence. [pmid: 11483831].
Kilander A F, Nilsson L A, Gillberg R. Serum antibodies to gliadin in coeliac disease after gluten withdrawal. Scand J Gastroenterol. 1987;22(1):29-34. Monitoring not serology, EMA, tTG or biopsy based, or not promoting GFD adherence. [pmid: 3563409].
King David S. Psychological and behavioral effects of food and chemical exposure in sensitive individuals. Nutr Health. 1984;3(3):137-151. Not relevant to adherence. [pmid: 6400044].
Kitts D, Yuan Y, Joneja J, et al. Adverse reactions to food constituents: allergy, intolerance, and autoimmunity. Can J Physiol Pharmacol. 1997;75(4):241-254. Not relevant to adherence. [pmid: 9196849].
Kjeldsen-Kragh J. Rheumatoid arthritis treated with vegetarian diets. Am J Clin Nutr. 1999;70(3 Suppl):594S-600S. Not relevant to adherence. [pmid: 10479237].
Kleiner S M. Sense and food sensitivity: Coping wit allergies and food intolerance. Phys Sportsmed. 1998;26(5):105-106. Not relevant to adherence. [pmid: 20086818].
Kluge F, Koch H K, Grosse-Wilde H, et al. Follow-up of treated adult celiac disease: clinical and morphological studies. Hepatogastroenterology. 1982;29(1):17-23. Not relevant to adherence. [pmid: 7095732].
Kohout P. Small bowel permeability in diagnosis of celiac disease and monitoring of compliance of a gluten-free diet (gut permeability in celiac disease). Acta Medica (Hradec Kralove). 2001;44(3):101-104. No monitoring measure of interest. [pmid: 11811077].
Kokkonen J, Viitanen A, Simila S. Coping with a coeliac diet after adolescence. Helv Paediatr Acta. 1989;43(4):261-265. Not relevant to adherence. [pmid: 2708068].
Kolsteren M M, Koopman H M, Schalekamp G, et al. Health-related quality of life in children with celiac disease. Eur J Pediatr. 2001;138(4):593-595. Not relevant to adherence.
Korponay-Szabo I R, Kovacs J B, Lorincz M, et al. Prospective significance of antiendomysium antibody positivity in subsequently verified celiac disease. J Pediatr Gastroenterol Nutr. 1997;25(1):56-63. Not relevant to adherence. [pmid: 9226528].
Kuitunen M, Savilahti E. Gut permeability to human alpha-lactalbumin, beta-lactoglobulin, mannitol, and lactulose in celiac disease. J Pediatr Gastroenterol Nutr. 1996;22(2):197-204. Not relevant to adherence. [pmid: 8642494].
Kumar P J, Walker-Smith J, Milla P, et al. The teenage coeliac: follow up study of 102 patients. Arch Dis Child. 1988;63(8):916-920. Not relevant to adherence. [pmid: 3415327].
Kumar P J. Commentary: are patients any better at adhering to a gluten-free diet?. Ital J Gastroenterol Hepatol. 1997;29(4):310-311. Not relevant to adherence. [pmid: 9476182].
Kumar V, Jarzabek-Chorzelska M, Sulej J, et al. Celiac disease and immunoglobulin A deficiency: How effective are the serological methods of diagnosis?. Clin Diagn Lab Immunol. 2002;9(6):1295-1300. Not relevant to adherence. [pmid: 12414763]. [pmcid: 130112].
Kumar V, Lerner A, Valeski J E, et al. Endomysial antibodies in the diagnosis of celiac disease and the effect of gluten on antibody titers. Immunol Invest. 1989;18(14):533-544. Not relevant to adherence. [pmid: 2499536].
Kutlu T, Brousse N, Rambaud C, et al. Numbers of T cell receptor (TCR) alpha beta+ but not of TcR gamma delta+ intraepithelial lymphocytes correlate with the grade of villous atrophy in coeliac patients on a long term normal diet. Gut. 1993;34(2):208-214. Not relevant to adherence. [pmid: 8432475]. [pmcid: 1373972].
Labrooy J T, Hohmann A W, Davidson G P, et al. Intestinal and serum antibody in coeliac disease: a comparison using ELISA. Clinical and Experimental Immunology. 1986;66(3):661-668. Not relevant to adherence. [pmid: 3568454]. [pmcid: 1542459].
Lahteenoja H, Toivanen A, Viander M, et al. Increase in T-cell subsets of oral mucosa: a late immune response in patients with treated coeliac disease?. Scand J Immunol. 2000;52(6):602-608. Not relevant to adherence. [pmid: 11119267].
Lahteenoja H, Toivanen A, Viander M, et al. Oral mucosal changes in coeliac patients on a gluten-free diet. Eur J Oral Sci. 1998;106(5):899-906. Not relevant to adherence. [pmid: 9786318].
Lancaster-Smith M, Joyce S, Kumar P. Immunoglobulins in the jejunal mucosa in adult coeliac disease and dermatitis herpetiformis after the reintroduction of dietary gluten. Gut. 1977;18(11):887-891. Not relevant to adherence. [pmid: 338443]. [pmcid: 1411725].
Lancaster-Smith M, Kumar P, Clark M L, et al. Antireticulin antibodies in dermatitis herpetiformis and adult coeliac disease. Their relationship to a gluten free diet and jejunal histology. Br J Dermatol. 1975;92(1):37-42. Not relevant to adherence. [pmid: 1156543].
Lancaster-Smith M, Packer S, Kumar P J, et al. Immunological phenomena in the jejunum and serum after reintroduction of dietary gluten in children with treated coeliac disease. J Clin Pathol. 1976;29(7):592-597. Not relevant to adherence. [pmid: 977769]. [pmcid: 476123].
Langman M J. Can epidemiology help us prevent celiac disease?. Gastroenterology. 1986;90(2):489-491. Not relevant to adherence. [pmid: 3484457].
Lankisch P G, Martinez Schramm A, Petersen F, et al. Diagnostic intervals for recognizing celiac disease. Z Gastroenterol. 1996;34(8):473-477. Not relevant to adherence. [pmid: 8794542].
Laurin P, Falth-Magnusson K, Sundqvist T. Increase in nitric oxide urinary products during gluten challenge in children with coeliac disease. Scand J Gastroenterol. 2003;38(1):55-60. Not relevant to adherence. [pmid: 12608465].
Laurin P, Wolving M, Falth-Magnusson K. Even small amounts of gluten cause relapse in children with celiac disease. J Pediatr Gastroenterol Nutr. 2002;34(1):26-30. Not relevant to adherence. [pmid: 11753160].
Layer P, Keller J. Lipase supplementation therapy: Standards, alternatives, and perspectives. Pancreas. 2003;26(1):1-7. Not relevant to adherence. [pmid: 12499909].
Le Quellec A, Clapie M, Callamand P, et al. Circulating oxyntomodulin-like immunoreactivity in healthy children and children with celiac disease. J Pediatr Gastroenterol Nutr. 1998;27(5):513-518. Not relevant to adherence. [pmid: 9822314].
Lehmann F G, Hillert U. Fecal intestinal alkaline phosphatase in coeliac disease. Z Gastroenterol. 1980;18(7):381-388. Not relevant to adherence. [pmid: 7424078].
Lemieux B, Boivin M, Brossard J H, et al. Normal parathyroid function with decreased bone mineral density in treated celiac disease. Can J Gastroenterol. 2001;15(5):302-307. Not relevant to adherence. [pmid: 11381297].
Leonard S. No grain, no pain. Nurs Times. 1999;95(8):69-70. Not relevant to adherence. [pmid: 10326527].
Levi S, Bjarnason I, Swinson C M, et al. Malignant pancreatic somatostatinoma in a patient with dermatitis herpetiformis and coeliac disease. Digestion. 1988;39(1):1-6. Not relevant to adherence. [pmid: 2899527].
Lewis C, Book L, Black J, et al. Celiac disease and human leukocyte antigen genotype: Accuracy of diagnosis in self-diagnosed individuals, dosage effect, and sibling risk. J Pediatr Gastroenterol Nutr. 2000;31(1):22-27. Not relevant to adherence. [pmid: 10896066].
Lifschitz C H, Polanco I, Lobb K. The urinary excretion of polyethylene glycol as a test for mucosal integrity in children with celiac disease: comparison with other noninvasive tests. J Pediatr Gastroenterol Nutr. 1989;9(1):49-57. No monitoring measure of interest. [pmid: 2778569].
Lindberg T, Nilsson L A, Borulf S, et al. Serum IgA and IgG gliadin antibodies and small intestinal mucosal damage in children. J Pediatr Gastroenterol Nutr. 1985;4(6):917-922. Not relevant to adherence. [pmid: 4067780].
Littlewood J M. Coeliac disease in childhood. Bailliere's Clinical Gastroenterology. 1995;9(2):295-327. Not relevant to adherence. [pmid: 7549029].
Lloyd-Still J D. Chronic diarrhea of childhood and the misuse of elimination diets. Eur J Pediatr. 1979;95(1):10-13. Not relevant to adherence.
Lohiniemi S, Maki M, Kaukinen K, et al. Gastrointestinal symptoms rating scale in coeliac disease patients on wheat starch-based gluten-free diets. Scand J Gastroenterol. 2000;35(9):947-949. Not relevant to adherence. [pmid: 11063154].
Lohiniemi S. Coeliac disease. Tricky to find, hard to treat, impossible to cure. Lancet. 2001;358(Suppl):14. Not relevant to adherence. [pmid: 11784563].
Londei M, Quaratino S, Maiuri L. Celiac disease: A model autoimmune disease with gene therapy applications. Hum Gene Ther. 2003;10(10):835-843. Not relevant to adherence.
Lorini R, Scotta M S, Cortona L, et al. Celiac disease and type I (insulin-dependent) diabetes mellitus in childhood: follow-up study. J Diabetes Complications. 1996;10(3):154-159. Not relevant to adherence. [pmid: 8807465].
Lovik A, Fluge Holsdal E R, Ek J, et al. Dietary Treatment of Coeliac Disease. Tidsskr Nor Laegeforen. 1999;119(13):1888-1891. Not relevant to adherence. [pmid: 10382335].
Lynch D A, Thornton J R, Axon A T. Acute fatty liver complicating coeliac disease. Eur J Gastroenterol Hepatol. 1994;6(8):745-747. Not relevant to adherence.
Mackner L M, McGrath A M, Stark L J. Dietary recommendations to prevent and manage chronic pediatric health conditions: Adherence, intervention, and future directions. J Dev Behav Pediatr. 2001;22(2):130-143. Not relevant to adherence. [pmid: 11332783].
Maffei H V, Kingston D, Hill I D, et al. Histopathologic changes and the immune response within the jejunal mucosa in infants and children. Pediatr Res. 1979;13(6):733-736. Not relevant to adherence. [pmid: 384350].
Magliocca F M, Bonamico M, Petrozza V, et al. A new morphological classification during follow-up in patients with celiac disease: a three-dimensional observation by scanning electron microscopy. Histol Histopathol. 1996;11(2):343-350. Not relevant to adherence. [pmid: 8861756].
Magrath G, Hartland B V. Dietary recommendations for children and adolescents with diabetes: An implementation paper. J Hum Nutr Diet. 1993;6(6):491-507. Not relevant to adherence.
Mainardi E, Montanelli A, Dotti M, et al. Thyroid-related autoantibodies and celiac disease: A role for a gluten-free diet?. J Clin Gastroenterol. 2002;35(3):245-248. Not relevant to adherence. [pmid: 12192201].
Maki M, Lahdeaho M L, Hallstrom O, et al. Postpubertal gluten challenge in coeliac disease. Arch Dis Child. 1989;64(11):1604-1607. Not relevant to adherence. [pmid: 2604420].
Maki M, Sulkanen S, Collin P. Antibodies in relation to gluten intake. Dig Dis. 1998;16(6):330-332. Review article. [pmid: 10207216].
Mariani P, Viti M G, Montuori M, et al. The gluten-free diet: a nutritional risk factor for adolescents with celiac disease?. J Pediatr Gastroenterol Nutr. 1998;27(5):519-523. Not relevant to adherence. [pmid: 9822315].
Matek Z, Jungvirth-Hegedus M, Kolacek S. Epidemiology of coeliac disease in children in one Croatian county: possible factors that could affect the incidence of coeliac disease and adherence to a gluten-free diet (Part II). Coll Antropol. 2000;24(2):397-404. Not relevant to adherence. [pmid: 11216408].
Mauro A, Orsi L, Mortara P, et al. Cerebellar Syndrome in Adult Celiac Disease With Vitamin E Deficiency. Acta Neurol Scand. 1991;84(2):167-170. Not relevant to adherence. [pmid: 1950453].
Mautalen C, Gonzalez D, Mazure R, et al. Effect of treatment on bone mass, mineral metabolism, and body composition in untreated celiac disease patients. Am J Gastroenterol. 1997;92(2):313-318. Not relevant to adherence. [pmid: 9128314].
McCarthy D M, Coleman M. Response of intestinal mucosa to gluten challenge in autistic subjects. Lancet. 1979;2(8148):877-878. Not relevant to adherence. [pmid: 90968].
McCrae W M, Eastwood M A, Martin M R, et al. Neglected coeliac disease. Lancet. 1975;1(7900):187-190. Not relevant to adherence. [pmid: 47419].
McElvaney N G, Duignan R, Fielding J F. Coeliac disease: clinical presentations, correlations of dietary compliance, symptomatic response and repeat biopsy findings. Ulster Med J. 1992;61(2):134-138. No correlations with other measures. [pmid: 1481302].
McFarlane X A, Bhalla A K, Robertson D A. Effect of a gluten free diet on osteopenia in adults with newly diagnosed coeliac disease. Gut. 1996;39(2):180-184. Not relevant to adherence. [pmid: 8991855]. [pmcid: 1383295].
McLoughlin R, Sebastian S S, Qasim A, et al. Coeliac disease in Europe. Aliment Pharmacol Ther Suppl. 2003;18(3):45-48. Not relevant to adherence.
McMillan S A, Dickey W, Douglas J P, et al. Transthyretin values correlate with mucosal recovery in patients with coeliac disease taking a gluten free diet. J Clin Pathol. 2001;54(10):783-786. Not relevant to adherence. [pmid: 11577127]. [pmcid: 1731281].
McNeish A S, Harms H K, Hey J, et al. The diagnosis of coeliac disease. A commentary on the current practices of members of the European Society for Paediatric Gastroenterology and Nutrition (ESPGAN). Arch Dis Child. 1979;54(10):783-786. Not relevant to adherence. [pmid: 507902].
McNeish A S. Coeliac disease: Duration of gluten-free diet. Arch Dis Child. 1980;55(2):110-111. Not relevant to adherence. [pmid: 7377831].
McNicholl B. Coeliac disease: ecology, life history and management. Human Nutrition. Applied Nutrition. 1986;40(Suppl 1):55-60. Not relevant to adherence. [pmid: 3528073].
McNicholl B. Management of coeliac disease. Midwife Health Visit Community Nurse. 1986;22(10):361-364. Not relevant to adherence. [pmid: 3641002].
McPhillips J. Understanding coeliac disease: symptoms and long-term risks. Br J Nurs. 2000;9(8):479-483. Not relevant to adherence. [pmid: 11143669].
Mearin M L, Koninckx C R, Biemond I, et al. Influence of genetic factors on the serum levels of antigliadin antibodies in celiac disease. J Pediatr Gastroenterol Nutr. 1984;3(3):373-377. Not relevant to adherence. [pmid: 6588183].
Meyer D, Stavropolous S, Diamond B, et al. Osteoporosis in a north american adult population with celiac disease. Am J Gastroenterol. 2001;96(1):112-119. Not relevant to adherence. [pmid: 11197239].
Michalski J P, McCombs C C. Celiac disease: Clinical features and pathogenesis. Am J Med Sci. 1994;307(3):204-211. Not relevant to adherence. [pmid: 8160711].
Mitchell R M S, Robinson T J. Monitoring dietary compliance in coeliac disease using red cell distribution width. Int J Clin Pract. 2002;56(4):249-250. No monitoring measure of interest. [pmid: 12074205].
Mitchison H C, al Mardini H, Gillespie S, et al. A pilot study of fluticasone propionate in untreated coeliac disease. Gut. 1991;32(3):260-265. Not relevant to adherence. [pmid: 1901562]. [pmcid: 1378830].
Mitt K, Uibo O. Low cereal intake in Estonian infants: The possible explanation for the low frequency of coeliac disease in Estonia. Eur J Clin Nutr. 1998;52(2):85-88. Not relevant to adherence. [pmid: 9505150].
Mobacken H, Andersson H, Gillberg R. Gluten-free diet in clinical practice: a Scandinavian perspective. Clin Dermatol. 1991;9(3):415-419. Not relevant to adherence. [pmid: 1806230].
Mokhallalaty M, Debek A, Naja Z, et al. Celiac disease at Makassed General Hospital (8 years of experience). Revue Medicale Libanaise. 2002;14(23):49-53. Not relevant to adherence.
Moll-Kotowski M, Stern M. Dietary attitude and follow-up in coeliac patients diagnosed 1964-1986. Monatsschr Kinderheilkd. 1995;143(2):142-148. Not relevant to adherence.
Molteni N, Bardella M T, Vezzoli G, et al. Intestinal calcium absorption as shown by stable strontium test in celiac disease before and after gluten-free diet. Am J Gastroenterol. 1995;90(11):2025-2028. Not relevant to adherence. [pmid: 7485015].
Monteiro E, Menezes M L, Magalhaes Ramalho P. Anti-reticulin antibodies: a diagnostic and monitoring test for childhood coeliac disease. Scand J Gastroenterol. 1986;21(8):955-957. Monitoring not serology, EMA, tTG or biopsy based, or not promoting GFD adherence. [pmid: 3535013].
Mora S, Barera G, Beccio S, et al. A prospective, longitudinal study of the long-term effect of treatment on bone density in children with celiac disease. Eur J Pediatr. 2001;139(4):516-521. Not relevant to adherence.
Mora S, Barera G, Beccio S, et al. Bone density and bone metabolism are normal after long-term gluten-free diet in young celiac patients. Am J Gastroenterol. 1999;94(2):398-403. Not relevant to adherence. [pmid: 10022636].
Mora S, Barera G, Ricotti A, et al. Reversal of low bone density with a gluten-free diet in children and adolescents with celiac disease. Am J Clin Nutr. 1998;67(3):477-481. Not relevant to adherence. [pmid: 9497193].
Mora S, Weber G, Barera G, et al. Effect of gluten-free diet on bone mineral content in growing patients with celiac disease. Am J Clin Nutr. 1993;57(2):224-228. Not relevant to adherence. [pmid: 8424392].
Morley J E. Pathophysiology of anorexia. Clin Geriatr Med. 2002;18(4):661-673. Not relevant to adherence. [pmid: 12608509].
Morris M A, Ciclitira P J. Coeliac disease. J R Coll Physicians Lond. 1997;31(6):614-618. Not relevant to adherence. [pmid: 9409492].
Morroni M, Sbarbati A, D'Angelo G, et al. Scanning electron microscopy of the small intestine mucosa in children with celiac disease after long-term dietary treatment. Scanning Microsc. 1989;3(4):1161-1166. Not relevant to adherence. [pmid: 2633334].
Mortimer P E, Stewart J S, Norman A P, et al. Follow-up study of coeliac disease. Br Med J. 1968;3(609):7-9. Not relevant to adherence. [pmid: 5661931]. [pmcid: 1989483].
Mowat A M. Coeliac disease - A future for peptide therapy?. Lancet. 2000;356(9226):270-271. Not relevant to adherence. [pmid: 11071179].
Mulder C J J, Wahab P J, Moshaver B, et al. Refractory coeliac disease: A window between coeliac disease and enteropathy associated T cell lymphoma. Scandinavian Journal of Gastroenterology. Supplement. 2000;35(232):32-37. Not relevant to adherence.
Murphy D. Celiac sprue. Gastroenterology Nursing - the Official Journal of the Society of Gastroenterology Nurses and Associates. 1995;18(4):133-137. Not relevant to adherence. [pmid: 7654809].
Murphy M S, Sood M, Johnson T. Use of the lactose H2 breath test to monitor mucosal healing in coeliac disease. Acta Paediatr. 2002;91(2):141-144. No monitoring measure of interest. [pmid: 11951999].
Murray J A. The widening spectrum of celiac disease. Am J Clin Nutr. 1999;69(3):354-365. Not relevant to adherence. [pmid: 10195608].
Mustalahti Kirsi, Lohiniemi Susanna, Collin Pekka, et al. Gluten-free diet and quality of life in patients with screen-detected celiac disease. Effective Clinical Practice - Ecp. 2002;5(3):105-113. Not relevant to adherence. [pmid: 12088289].
Muzzo S, Burrows R, Burgueno M, et al. Effect of calcium and vitamin D supplementation on bone mineral density of celiac children. Nutr Res. 2000;20(9):1241-1247. Not relevant to adherence.
Naeslund G K, Fredrikson M, Hellenius M L, et al. Determinants of Compliance in Men Enrolled in a Diet and Exercise Intervention Trial: a Randomized, Controlled Study. Patient Education & Counseling. 1996;29(3):247-256. Not relevant to adherence. [pmid: 9006240].
Nash Samantha. Does exclusive breast-feeding reduce the risk of coeliac disease in children?. Br J Community Nurs. 2003;8(3):127-132. Not relevant to adherence. [pmid: 12682607].
Naveh Y, Ken-Dror A, Zinder O, et al. Comparative reliability of D-xylose absorption and serum beta-carotene measurements in small intestinal disease. J Pediatr Gastroenterol Nutr. 1986;5(2):210-213. Not relevant to adherence. [pmid: 3958848].
Nehra V. New clinical issues in celiac disease. Gastroenterol Clin North Am. 1998;27(2):453-465. Not relevant to adherence. [pmid: 9650027].
Nieminen U, Kahri A, Savilahti E, et al. Duodenal disaccharidase activities in the follow-up of villous atrophy in coeliac disease. Scand J Gastroenterol. 2001;36(5):507-510. Not relevant to adherence. [pmid: 11346204].
Norgard B, Fonager K, Sorensen H T, et al. Birth outcomes of women with celiac disease: A nationwide historical cohort study. Am J Gastroenterol. 1999;94(9):2435-2440. Not relevant to adherence. [pmid: 10484005].
not found, in reference. Nutritional problems and controversies in gastrointestinal diseases. Nutrition in Practice 1982;2(1):3–32. Not relevant to adherence
Not T, Tommasini A, Tonini G, et al. Undiagnosed coeliac disease and risk of autoimmune disorders in subjects with type I diabetes mellitus. Diabetologia. 2001;44(2):151-155. Not relevant to adherence. [pmid: 11270670].
Novacek G, Miehsler W, Wrba F, et al. Prevalence and clinical importance of hypertransaminasaemia in coeliac disease. Eur J Gastroenterol Hepatol. 1999;11(3):283-288. Not relevant to adherence. [pmid: 10333201].
Nowowiejska B, Kaczmarski M, Dabrowska E J. A long-term study in children with a recognized gluten intolerance. Rocz Akad Med Bialymst. 1995;40(3):580-587. No monitoring measure of interest. [pmid: 8775310].
Ogborn A D. Pregnancy in patients with coeliac disease. Br J Obstet Gynaecol. 1975;82(4):293-296. Not relevant to adherence. [pmid: 1125150].
O'Halloran E T, Read M, Morrissey-Walsh E M. Coeliac disease in children: Problems in diagnosis and management. Ir Med J. 1985;78(7):188-191. Not relevant to adherence. [pmid: 4030295].
O'Leary Clare, Wieneke Peter, Buckley Sarah, et al. Celiac disease and irritable bowel-type symptoms. Am J Gastroenterol. 2002;97(6):1463-1467. Not relevant to adherence. [pmid: 12094866].
Olives PrJ. Coeliac disease and gluten intolerance: New data for a new method of treatment. Rev Med Liban. 2000;12(3):127-128. Not relevant to adherence.
O'Mahony S, Nawroz I M, Ferguson A. Coeliac disease and collagenous colitis. Postgrad Med J. 1990;66(773):238-241. Not relevant to adherence. [pmid: 2362896].
Ott D J. Celiac disease: biopsy or enteroclysis better for evaluating response to a gluten-free diet?. Am J Gastroenterol. 1997;92(4):715-716. Review article. [pmid: 9382045].
Packer S, Rowlatt R J, Harries J T. Proceedings: Reappraisal of a past diagnosis of “coeliac disease”. Arch Dis Child. 1974;49(10):819. Not relevant to adherence. [pmid: 4429369].
Paerregaard A, Vilien M, Krasilnikoff P A, et al. Supposed coeliac disease during childhood and its presentation 14–38 years later. Scand J Gastroenterol. 1988;23(1):65-70. Not relevant to adherence. [pmid: 3344399].
Page S R, Lloyd C A, Hill P G, et al. The prevalence of coeliac disease in adult diabetes mellitus. Q J Med. 1994;87(10):631-637. Not relevant to adherence.
Parker S L, Sussman G L, Krondl M. Dietary aspects of adverse reactions to foods in adults. Cmaj - Canadian Medical Association Journal = Journal De L'association Medicale Canadienne. 1988;139(8):711-718. Not relevant to adherence.
Paterson Heather. Plant foods for coeliacs. Food Nutr Notes Rev. 1975;32(1112):205-209. Not relevant to adherence.
Patin N M, Johnson F, Kirks B A. Promoting dietary compliance in gluten-intolerant children. J Nutr Educ. 1989;21(2):100D. Not relevant to adherence.
Patwari A K, Anand V K, Kapur Gaurav, et al. Clinical and nutritional profile of children with celiac disease. Indian Pediatr. 2003;40(4):337-342. Not relevant to adherence. [pmid: 12736407].
Peraaho M, Kaukinen K, Paasikivi K, et al. Wheat-starch-based gluten-free products in the treatment of newly detected coeliac disease: prospective and randomized study. Aliment Pharmacol Ther. 2003;17(4):587-594. Not relevant to adherence. [pmid: 12622768].
Peters Ulrike, Askling Johan, Gridley Gloria, et al. Causes of death in patients with celiac disease in a population-based Swedish cohort. Arch Intern Med. 2003;163(13):1566-1572. Not relevant to adherence. [pmid: 12860579].
Pistorius L R, Sweidan W H, Purdie D W, et al. Coeliac disease and bone mineral density in adult female patients. Gut. 1995;37(5):639-642. Not relevant to adherence. [pmid: 8549938]. [pmcid: 1382867].
Polito C, Olivieri A N, Marchese L, et al. Weight overgrowth of coeliac children on gluten-free diet. Nutr Res. 1992;12(3):353-358. Not relevant to adherence.
Pruessner H T. Detecting celiac disease in your patients. Am Fam Physician. 1998;57(5):1023-1034. Not relevant to adherence. [pmid: 9518950].
Pueschel S M. Gastrointestinal concerns and nutritional issues in persons with Down syndrome. Down Syndrome Quarterly. 1999;4(4):1-11. Not relevant to adherence.
Pynnoenen P, Isometsae E T, Verkasalo M A, et al. Untreated Celiac Disease and Development of Mental Disorders in Children and Adolescents. Psychosomatics: Journal of Consultation Liaison Psychiatry. 2002;43(4):331-334. Not relevant to adherence.
Radzikowski A, Kulus M, Krauze A, et al. Growth, bone age and nutritional status in neglected coeliac disease. Materia Medica Polona. Polish Journal of Medicine and Pharmacy. 1991;23(2):146-150. Not relevant to adherence. [pmid: 1842603].
Rautonen J, Rautonen N, Savilahti E. Antibodies to gliadin in children with coeliac disease. Acta Paediatr Scand. 1991;80(12):1200-1206. Monitoring not serology, EMA, tTG or biopsy based, or not promoting GFD adherence. [pmid: 1785292].
Rea F, Polito C, Marotta A, et al. Restoration of body composition in celiac children after one year of gluten-free diet. J Pediatr Gastroenterol Nutr. 1996;23(4):408-412. Not relevant to adherence. [pmid: 8956176].
Read M, O'Halloran E T, O'sullivan C. Coeliac disease in adolescents/young adults: difficulties in monitoring. Br J Biomed Sci. 2000;57(3):217-221. No correlations with other measures. [pmid: 11050774].
Reeves G E M, Burns C, Hall S T, et al. The measurement of IgA and IgG transglutaminase antibodies in celiac disease: A comparison with current diagnostic methods. Pathology. 2000;32(3):181-185. Monitoring not serology, EMA, tTG or biopsy based, or not promoting GFD adherence. [pmid: 10968391].
Reifen R, Reif S, Buskila D, et al. Transthyretin: a marker for celiac disease activity. J Med. 1998;29(12):30-36. No monitoring measure of interest. [pmid: 9704290].
Reunala T, Chorzelski T P, Viander M, et al. IgA anti-endomysial antibodies in dermatitis herpetiformis: correlation with jejunal morphology, gluten-free diet and anti-gliadin antibodies. Br J Dermatol. 1987;117(2):185-191. Not relevant to adherence. [pmid: 3651340].
Ricart E, Bouma G, Salvador Pen, et al. The therapeutic spectrum of infliximab and tumor necrosis factor immunomodulation in chronic inflammatory diseases. Drugs Today. 2002;38(11):725-744. Not relevant to adherence. [pmid: 12582457].
Robert M E, Ament M E, Weinstein W M. The histologic spectrum and clinical outcome of refractory and unclassified sprue. Am J Surg Pathol. 2000;24(5):676-687. Not relevant to adherence. [pmid: 10800986].
Roizen N J, Patterson D. Down Syndrome. Lancet. 2003;361(9365):1281-1289. Not relevant to adherence. [pmid: 12699967].
Rolles C J, Anderson M, McNeish A S. Confirming persistence of gluten intolerance in children diagnosed as having coeliac disease in infancy. Arch Dis Child. 1975;50(4):259-263. Not relevant to adherence. [pmid: 1147665].
Rolles C J. Proceedings: Usefulness of a modified D-xylose absorption test in the preliminary diagnosis of coeliac disease and its later confirmation. Arch Dis Child. 1973;48(10):825. Not relevant to adherence. [pmid: 4749691].
Romaldini Ceres C, Barbieri Dorina, Okay Thelma S, et al. Serum soluble interleukin-2 receptor, interleukin-6, and tumor necrosis factor-alpha levels in children with celiac disease: response to treatment. J Pediatr Gastroenterol Nutr. 2002;35(4):513-517. Monitoring not serology, EMA, tTG or biopsy based, or not promoting GFD adherence. [pmid: 12394376].
Rosekrans P C, Meijer C J, Polanco I, et al. Long-term morphological and immunohistochemical observations on biopsy specimens of small intestine from children with gluten-sensitive enteropathy. J Clin Pathol. 1981;34(2):138-144. Not relevant to adherence. [pmid: 7229092]. [pmcid: 1146439].
Roter D L, Hall J A, Merisca R, et al. Effectiveness of Interventions to Improve Patient Compliance - a Meta-Analysis. Med Care. 1998;36(8):1138-1161. Not relevant to adherence. [pmid: 9708588].
Russell J A. Osteomalacic myopathy. Muscle Nerve. 1994;17(6):578-580. Not relevant to adherence. [pmid: 8196699].
Ryan J. Coeliac disease. Update 2000. Aust Fam Physician. 2000;29(9):835-838. Not relevant to adherence. [pmid: 11008385].
Sampson H A. 9. Food allergy. J Allergy Clin Immunol. 2003;111(2 Suppl 2):S540-S547. Not relevant to adherence. [pmid: 14657884].
Sanders S W, Zone J J. The relationship between dapsone dose, serum concentration and disease severity in dermatitis herpetiformis. Arzneim-Forsch Drug Res. 1986;36(1):146-149. Not relevant to adherence. [pmid: 3954818].
Sategna Guidetti C, Solerio E, Scaglione N, et al. Duration of gluten exposure in adult coeliac disease does not correlate with the risk for autoimmune disorders. Gut. 2001;49(4):502-505. Not relevant to adherence. [pmid: 11559646]. [pmcid: 1728461].
Sategna Guidetti, Carla Scaglione, Nadia Martini, et al. Red cell distribution width as a marker of coeliac disease: a prospective study. Eur J Gastroenterol Hepatol. 2002;14(2):177-181. Not relevant to adherence. [pmid: 11981342].
Sategna-Guidetti C, Grosso S B, Bruno M, et al. Is human umbilical cord the most suitable substrate for the detection of endomysium antibodies in the screening and follow-up of coeliac disease?. Eur J Gastroenterol Hepatol. 1997;9(7):657-660. Not relevant to adherence. [pmid: 9262972].
Sategna-Guidetti C, Grosso S B, Grosso S, et al. The effects of 1-year gluten withdrawal on bone mass, bone metabolism and nutritional status in newly-diagnosed adult coeliac disease patients. Alimentary Pharmacology & Therapeutics. 2000;14(1):35-43. No correlations with other measures. [pmid: 10632643].
Sategna-Guidetti C, Volta U, Ciacci C, et al. Prevalence of thyroid disorders in untreated adult celiac disease patients and effect of gluten withdrawal: an Italian multicenter study. Am J Gastroenterol. 2001;96(3):751-757. Not relevant to adherence. [pmid: 11280546].
Scalici C, Manzoni D, Licastro G, et al. Celiac disease in the pediatric age, psychological difficulties experienced on the gluten-free diet. A preliminary investigation at the Clinic for Celiac Disease of the “G. Di Cristina” Hospital ARNAS, Palermo, Italy. Arch Mediterr Med. 2003;19(1):63-66. Not relevant to adherence.
Schenk E A, Samloff I M. Clinical and morphologic changes following gluten administration to patients with treated celiac dsease. Am J Pathol. 1968;52(3):579-593. Not relevant to adherence. [pmid: 5642926]. [pmcid: 2013423].
Schmitz J. Is celiac disease a lifelong disorder?. Clinical and Investigative Medicine. Medecine Clinique Et Experimentale. 1996;19(5):352-356. Not relevant to adherence. [pmid: 8889273].
Schutz S M, Stroebel J, Schutz E M, et al. Celiac sprue. Diagnosis and diet: keys to recovery. N C Med J. 1994;55(1):32-36. Not relevant to adherence. [pmid: 8121500].
Schwartz M K, Sleisenger M H, Pert J H et al. The effect of a gluten-free diet on fat, nitrogen, and mineral metabolism in patients with sprue. Gastroenterology 1968;54(4):SupplNot relevant to adherence
Scott E M, Gaywood I, Scott B B. Guidelines for osteoporosis in coeliac disease and inflammatory bowel disease. British Society of Gastroenterology. Gut 2000;46(Suppl 1):-1. Not relevant to adherence
Scott H, Brandtzaeg P. Pathogenesis of food protein intolerance. Acta Paediatr Scand 1989;(Suppl 351):48–52. Not relevant to adherence
Sdepanian V L, Morais M B, Scaletsky I C A, et al. Evaluation of theoretical knowledge of celiac disease and practical knowledge in preparing gluten-free foods by celiac patients. Pediatrika. 2001;21(8):39-44. Not relevant to adherence.
Secker-Walker R H, Morrow A L, Kresnow M J, Flynn B S. Family Physician's Attitudes About Dietary Advice. Fam Pract Res J. 1991;11(2):161-170. Not relevant to adherence. [pmid: 2058408].
Seraphin P, Mobarhan S. Mortality in patients with celiac disease. Nutr Rev. 2002;60(4):116-118. Not relevant to adherence. [pmid: 12002682].
Shamir R, Levine A, Yalon-Hacohen M, et al. Faecal occult blood in children with coeliac disease. Eur J Pediatr. 2000;159(11):832-834. Not relevant to adherence. [pmid: 11079196].
Sheldon W. Prognosis in early adult life of coeliac children treated with a gluten-free diet. Br Med J. 1969;2(654):401-404. Not relevant to adherence. [pmid: 5781486]. [pmcid: 1983338].
Sher K S, Mayberry J F. Female fertility, obstetric and gynaecological history in coeliac disease: a case control study. Acta Paediatrica.Supplement 1996;41276–77. Not relevant to adherence
Shmerling D H, Franckx J. Childhood celiac disease: a long-term analysis of relapses in 91 patients. J Pediatr Gastroenterol Nutr. 1986;5(4):565-569. Not relevant to adherence. [pmid: 3735007].
Sicherer S H, Sampson H A. Food hypersensitivity and atopic dermatitis: Pathophysiology, epidemiology, diagnosis, and management. J Allergy Clin Immunol. 1999;104(3 II):S114-S122. Not relevant to adherence. [pmid: 10482862].
Signore A, Chianelli M, Annovazzi A, et al. Imaging active lymphocytic infiltration in coeliac disease with iodine-123-interleukin-2 and the response to diet. European Journal of Nuclear Medicine. 2000;27(1):18-24. No correlations with other measures. [pmid: 10654142].
Silink M. How should we manage celiac disease in childhood diabetes?. Pediatr Diabetes. 2001;2(3):95-97. Not relevant to adherence. [pmid: 15016190].
Sklar M, Kirsner J B. Assessing and interviewing the elderly: Interpretation of signs and symptoms. Bailliere's Best Pract Res Clin Gastroenterol. 2001;15(6):851-867. Not relevant to adherence.
Smecuol E, Gonzalez D, Mautalen C, et al. Longitudinal study on the effect of treatment on body composition and anthropometry of celiac disease patients. Am J Gastroenterol. 1997;92(4):639-643. Not relevant to adherence. [pmid: 9128314].
Spiller R C. Postinfectious irritable bowel syndrome. Gastroenterology. 2003;124(6):1662-1671. Not relevant to adherence. [pmid: 14724817].
Spollett G R. Nutritional management of common gastrointestinal problems. Nurse Pract Forum. 1994;5(1):24-27. Not relevant to adherence. [pmid: 8148654].
Srinivasan U, Jones E, Weir D G, et al. Lactase enzyme, detected immunohistochemically, is lost in active celiac disease, but unaffected by oats challenge. Am J Gastroenterol. 1999;94(10):2936-2941. Not relevant to adherence. [pmid: 10520848].
Stahlberg M R, Savilahti E, Siimes M A. Iron deficiency in coeliac disease is mild and it is detected and corrected by gluten-free diet. Acta Paediatr Scand. 1991;80(2):190-193. Not relevant to adherence. [pmid: 2035309].
Stenhammar L, Brandt A, Wagermark J. A family study of coeliac disease. Acta Paediatr Scand. 1982;71(4):625-628. Not relevant to adherence. [pmid: 7136679].
Stenhammar L, Kilander A F, Nilsson L A, et al. Serum gliadin antibodies for detection and control of childhood coeliac disease. Acta Paediatr Scand. 1984;73(5):657-663. Monitoring not serology, EMA, tTG or biopsy based, or not promoting GFD adherence. [pmid: 6485785].
Stenhammar L, Stromberg L, Kilander A F, et al. Plasma enteroglucagon in the control of childhood celiac disease. J Pediatr Gastroenterol Nutr. 1985;4(2):325-330. Not relevant to adherence. [pmid: 3989631].
Stenhammar L. Transient gastro-intestinal disorders during infancy and early childhood. A follow-up study with special reference to coeliac disease. Acta Paediatr Scand. 1981;70(3):383-387. Not relevant to adherence. [pmid: 7246130].
Stern M, Ciclitira P J, van Eckert R, et al. Analysis and clinical effects of gluten in coeliac disease. Eur J Gastroenterol Hepatol. 2001;13(6):741-747. Not relevant to adherence. [pmid: 11434606].
Stern M, Fischer K, Gruettner R. Gliadin antibodies in coeliac disease. Acta Paediatr Belg. 1977;30(4):252. Monitoring not serology, EMA, tTG or biopsy based, or not promoting GFD adherence.
Stewart J S. Clinical and morphologic response to gluten withdrawal. Clin Gastroenterol. 1974;3(1):109-126. Not relevant to adherence. [pmid: 4600387].
Stewart Truswell A. Therapeutic diets. Br Med J. 1985;291(6498):807-811. Not relevant to adherence. [pmid: 3929951]. [pmcid: 1417152].
Storsrud S, Olsson M, Arvidsson Lenner R, et al. Adult coeliac patients do tolerate large amounts of oats. Eur J Clin Nutr. 2003;57(1):163-169. Not relevant to adherence. [pmid: 12548312].
Storsrud Stine, Hulthen Lena R, Lenner Ragnhild A. Beneficial effects of oats in the gluten-free diet of adults with special reference to nutrient status, symptoms and subjective experiences. Br J Nutr. 2003;90(1):101-107. Not relevant to adherence. [pmid: 12844381].
Sullivan A. Coeliac disease. Nursing Standard (Royal College of Nursing (Great Britain) - 1987). 1999;14(11):48-52. Not relevant to adherence. [pmid: 11209312].
Sutton G. Coeliac disease: Testing the New Zealand iceberg. N Z J Med Lab Sci. 2000;54(2):46-48. No correlations with other measures.
Szathmari M, Tulassay T, Arato A, et al. Bone mineral content and density in asymptomatic children with coeliac disease on a gluten-free diet. Eur J Gastroenterol Hepatol. 2001;13(4):419-424. Not relevant to adherence. [pmid: 11338073].
Tai V, Crowe M, O'Keefe S. Celiac disease in older people. J Am Geriatr Soc. 2000;48(12):1690-1696. Not relevant to adherence. [pmid: 11129763].
Taylor S L, Hefle S L. Ingredient and labeling issues associated with allergenic foods. Allergy. 2001;56(Suppl 67):64-69. Not relevant to adherence. [pmid: 11298013].
Teeffelen-Heithoff A. Dietetic treatment of celiac disease. Monatsschr Kinderheilkd. 2003;151(7):719-725. Not relevant to adherence.
Thalayasingam B. Coeliac disease as a cause of osteomalacia and rickets in the Asian immigrant population. Br Med J. 1985;290(6475):1146-1147. Not relevant to adherence. [pmid: 3921135].
Thomas T. Helping coeliac disease patients adapt to a gluten-free diet. Community Nurse. 2000;6(6):19-22. Not relevant to adherence. [pmid: 12778645].
Thompson T. Do oats belong in a gluten-free diet?. J Am Diet Assoc. 1997;97(12):1413-1416. Not relevant to adherence. [pmid: 9404339].
Thompson T. Questionable foods and the gluten-free diet: survey of current recommendations. J Am Diet Assoc. 2000;100(4):463-465. Not relevant to adherence. [pmid: 11103663].
Thompson T. Wheat starch, gliadin, and the gluten-free diet. J Am Diet Assoc. 2001;101(12):1456-1459. Not relevant to adherence. [pmid: 11762742].
Thornquist H, Jacobsen G S, Dahl L B, et al. Coeliac disease and gluten-free diet: a following-up study of fifteen young adults. Ann Nutr Metab. 1993;37(6):295-301. Not relevant to adherence. [pmid: 8109888].
Tonder M, Sorlie D, Kearney M S. Adult coeliac disease: a case with ulceration, dermatitis herpetiformis and reticulosarcoma. Scand J Gastroenterol. 1976;11(1):107-111. Not relevant to adherence. [pmid: 766153].
Tonutti E, Visentini D, Bizzaro N, et al. The role of antitissue transglutaminase assay for the diagnosis and monitoring of coeliac disease: a French-Italian multicentre study. J Clin Pathol. 2003;56(5):389-393. Not relevant to adherence. [pmid: 12719462]. [pmcid: 1769943].
Trewby P N, Chipping P M, Palmer S J, et al. Splenic atrophy in adult coeliac disease: is it reversible?. Gut. 1981;22(8):628-632. Not relevant to adherence. [pmid: 7286779]. [pmcid: 1420073].
Troncone R, Caputo N, Micillo M, et al. Immunologic and intestinal permeability tests as predictors of relapse during gluten challenge in childhood coeliac disease. Scand J Gastroenterol. 1994;29(2):144-147. Not relevant to adherence. [pmid: 8171282].
Troncone R, Greco L, Mayer M, et al. In siblings of celiac children, rectal gluten challenge reveals gluten sensitization not restricted to celiac HLA. Gastroenterology. 1996;111(2):318-324. Not relevant to adherence. [pmid: 8690196].
Troncone R, Starita A, Coletta S, et al. Antigliadin antibody, D-xylose, and cellobiose/mannitol permeability tests as indicators of mucosal damage in children with coeliac disease. Scand J Gastroenterol. 1992;27(8):703-706. No monitoring measure of interest. [pmid: 1439555].
Troncone Riccardo, Franzese Adriana, Mazzarella Giuseppe, et al. Gluten sensitivity in a subset of children with insulin dependent diabetes mellitus. Am J Gastroenterol. 2003;98(3):590-595. Not relevant to adherence. [pmid: 12650792].
Tursi A, Brandimarte G, Giorgetti G M. Sorbitol H2-breath test versus anti-endomysium antibodies to assess histological recovery after gluten-free diet in coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(12):846-850. No correlations with other measures. [pmid: 12643292].
Tursi Antonio, Brandimarte Giovanni, Giorgetti GianMarco. High prevalence of small intestinal bacterial overgrowth in celiac patients with persistence of gastrointestinal symptoms after gluten withdrawal. Am J Gastroenterol. 2003;98(4):839-843. Not relevant to adherence. [pmid: 12738465].
Tursi Antonio, Brandimarte Giovanni. The symptomatic and histologic response to a gluten-free diet in patients with borderline enteropathy. J Clin Gastroenterol. 2003;36(1):13-17. Not relevant to adherence. [pmid: 12488700].
Twist S R, Hackett A F. An investigation of some implications of coeliac disease. J Hum Nutr Diet. 1992;5(6):343-350. Not relevant to adherence.
Uil J J, van Elburg R M, van Overbeek F M, et al. Follow-up of treated coeliac patients: sugar absorption test and intestinal biopsies compared. Eur J Gastroenterol Hepatol. 1996;8(3):219-223. No monitoring measure of interest. [pmid: 8724020].
Usai P, Minerba L, Marini B, et al. Case control study on health-related quality of life in adult coeliac disease. Digestive and Liver Disease - Official Journal of the Italian Society of Gastroenterology and the Italian Association for the Study of the Liver. 2002;34(8):547-552. Not relevant to adherence. [pmid: 12502210].
Vainio E, Kosnai I, Hallstrom O, et al. Antigliadin and antireticulin antibodies in children with dermatitis herpetiformis. J Pediatr Gastroenterol Nutr. 1986;5(5):735-739. Not relevant to adherence. [pmid: 3531458].
Valdimarsson T, Lofman O, Toss G, et al. Reversal of osteopenia with diet in adult coeliac disease. Gut. 1996;38(3):322-327. Not relevant to adherence. [pmid: 8675082]. [pmcid: 1383058].
Valdimarsson T, Toss G, Lofman O, et al. Three years' follow-up of bone density in adult coeliac disease: significance of secondary hyperparathyroidism. Scand J Gastroenterol. 2000;35(3):274-280. Not relevant to adherence. [pmid: 10766321].
van den, Bosch H C, Tham R T, et al. Celiac disease: small-bowel enteroclysis findings in adult patients treated with a gluten-free diet. Radiology. 1996;201(3):803-808. Not relevant to adherence. [pmid: 8939235].
Varkonyi A, Boda M, Endreffy E et al. Coeliac disease: always something to discover. Scandinavian Journal of Gastroenterology.Supplement 1998;228122–129. Not relevant to adherence
Vazquez H, Smecuol E, Flores D, et al. Relation between cigarette smoking and celiac disease: evidence from a case-control study. Am J Gastroenterol. 2001;96(3):798-802. Not relevant to adherence. [pmid: 11280554].
Vermeer B J, Lindeman J, Harst-Oostveen C J, et al. The immunoglobulin-bearing cells in the lamina propria and the clinical response to a gluten-free diet in dermatitis herpetiformis. Archives for Dermatological Research. Archiv Fur Dermatologische Forschung. 1977;258(3):223-230. Not relevant to adherence.
Vermeire E, Hearnshaw H, Van Royen P, et al. Patient Adherence to Treatment: Three Decades of Research. A Comprehensive Review. J Clin Pharm Ther. 2001;26(5):331-342. Not relevant to adherence. [pmid: 11679023].
Visakorpi J K, Kuitunen P, Savilahti E. Frequency and nature of relapses in children suffering from the malabsorption syndrome with gluten intolerance. Acta Paediatr Scand. 1970;59(5):481-486. Not relevant to adherence. [pmid: 5455517].
Vogelsang H, Propst A, Dragosics B, et al. Diagnosis and therapy of celiac disease in adolescence and adulthood. Z Gastroenterol. 2002;40(7):1-7. Not relevant to adherence. [pmid: 12199198].
Vogelsang H, Schwarzenhofer M, Oberhuber G. Changes in gastrointestinal permeability in celiac disease. Dig Dis. 1998;16(6):333-336. Review article. [pmid: 10207219].
Volta U, Cassani F, De Franchis R, et al. Antibodies to gliadin in adult coeliac disease and dermatitis herpetiformis. Digestion. 1984;30(4):263-270. Monitoring not serology, EMA, tTG or biopsy based, or not promoting GFD adherence. [pmid: 6391982].
Volta U, De Giorgio R, Petrolini N, et al. Clinical findings and anti-neuronal antibodies in coeliac disease with neurological disorders. Scand J Gastroenterol. 2002;37(11):1276-1281. Not relevant to adherence. [pmid: 12465725].
Vuoristo M, Tilvis R, Miettinen T A. Serum plant sterols and lathosterol related to cholesterol absorption in coeliac disease. Clinica Chimica Acta - International Journal of Clinical Chemistry. 1988;174(2):213-224. No monitoring measure of interest. [pmid: 3383445].
Wahab P J, Meijer Jos W R, Mulder Chris J J. Histologic follow-up of people with celiac disease on a gluten-free diet: slow and incomplete recovery. American Journal of Clinical Pathology. 2002;118(3):459-463. No correlations with other measures. [pmid: 12219789].
Walton C, Walton S. Primary biliary cirrhosis in a diabetic male with dermatitis herpetiformis. Clin Exp Dermatol. 1987;12(1):46-47. Not relevant to adherence. [pmid: 3446427].
Wauters E A, Jansen J, Houwen R H, et al. Serum IgG and IgA anti-gliadin antibodies as markers of mucosal damage in children with suspected celiac disease upon gluten challenge. J Pediatr Gastroenterol Nutr. 1991;13(2):192-196. Not relevant to adherence. [pmid: 1941413].
Weile B. Aspects of classic symptomatic childhood coeliac disease in Denmark: Retrospectively illustrated by local, regional, and national studies. APMIS Suppl. 2003;111(113):5-46. Not relevant to adherence. [pmid: 14626049].
Weir D G, Hourihane D O. Coeliac disease during the teenage period: the value of serial serum folate estimations. Gut. 1974;15(6):450-457. Not relevant to adherence. [pmid: 4851068]. [pmcid: 1413001].
Weizman Z, Ben Zion Y Z, Binsztok M, et al. Correlation of clinical characteristics and small bowel histopathology in celiac disease. J Pediatr Gastroenterol Nutr. 1997;24(5):555-558. Not relevant to adherence. [pmid: 9161951].
Westman E, Ambler G R, Royle M, et al. Children with coeliac disease and insulin dependent diabetes mellitus--growth, diabetes control and dietary intake. Journal of Pediatric Endocrinology & Metabolism - Jpem. 1999;12(3):433-442. Not relevant to adherence. [pmid: 10821223].
Wharton B, Wharton P. Nutrition in adolescence. Nutr Health. 1987;4(4):195-203. Not relevant to adherence. [pmid: 3554043].
Willis J. Coeliac disease: maintaining a gluten-free diet. Nurs Times. 1996;92(17):44-46. Not releant to adherence. [pmid: 9043349].
Young W F, Pringle E M. 110 children with coeliac disease, 1950-1969. Arch Dis Child. 1971;46(248):421-436. Not relevant to adherence. [pmid: 5109407].
Ziegler Anette, Schmid Sandra, Huber Doris, et al. Early Infant Feeding and Risk of Developing Type 1 Diabetes-Associated Autoantibodies. JAMA. 2003;290(13):1721-1728. Not relevant to adherence. [pmid: 14519706].
Zouganelis S, Priest M. Impact of dietary compliance on nutritional status in adult coeliac disease. Gut. 2001;48(Suppl 1):A42. No correlations with other measur.