# Appendix K. Additional Acknowledgements

The UO-EPC gratefully acknowledges the following individuals who served on our Technical Expert Panel (TEP). Acknowledgement does not reflect endorsement of this report.

- J Decker Butzner, MD
- Associate Professor Faculty of Medicine
- Dept. of Pediatrics Gastrointestinal Research Group
- Head, Division of Pediatric Gastroenterology and Nutrition
- Alberta Children's Hospital
- Calgary, AB

- Richard J Farrell, MD
- Gastroenterology Division
- Beth Israel Deaconess Medical Center
- Harvard Medical School
- Boston, MA

- Maha Guindi, MD
- Department of Laboratory Medicine and Pathobiology
- University of Toronto
- Department of Pathology, Toronto General Hospital
- Toronto, ON

- Connie Switzer, MD
- Division of Gastroenterology & Department of Medicine
- University of Alberta
- Chair of Professional Advisory Board, CCA
- Edmonton, AB

- Jerry Trier, MD
- Brigham and Women's Hospital
- Department of Medicine Gastroenterology
- Harvard Medical School
- Boston, MA

- Sander JOV van Zanten, MD
- Department of Medicine
- Dalhousie University
- Queen Elizabeth II Health Sciences Center
- Victoria General Site
- Halifax, NS

- *Charles O Elson III, MD
- Department of Medicine
- University of Birmingham
- Birmingham, AL

*Dr.Elson was named to the Technical Expert Panel given his position as Panel Chair of the NIH Consensus Conference on Celiac Disease

The UO-EPC gratefully acknowledges the following individuals who reviewed the initial draft of this evidence report, and provided constructive feedback. Acknowledgement does not reflect endorsement of this report.

- David Atkins, MD, MPH
- Chief Medical Officer
- Center for Outcomes and Evidence
- Agency for Healthcare Research Quality
- Rockville, MD

- Linda S. Book, MD
- Chief Pediatric Gastroenterology and Liver Transplantation
- University of Utah
- Primary Children's Medical Center
- Salt Lake City, UT

- William Depew, MD
- Department of Gastroenterology,
- Hotel Dieu Hospital
- Division of Gastroenterology
- Queen's University
- Kingston, ON

- Richard J Farrell, MD
- Gastroenterology Division
- Beth Israel Deaconess Medical Center
- Harvard Medical School,
- Boston, MA

- Martin R. Howard, MD
- Department of Haematology
- York District Hospital
- York, UK

- Richard A McPherson, MD
- Department of Pathology
- Medical College of Virginia Hospitals
- Richmond, VA

- Grant Thompson
- Faculty of Medicine, Gastroenterology
- University of Ottawa
- Ottawa, ON