# Appendix J. Quality Assessment

Table 1 Celiac 1 diagnostic studies (QUADAS)

Author (Year) | Item 1: spectrum of patients | Item 2: selection criteria | Item 3: reference standard | Item 4: time period | Item 5: sampling | Item 6: test result | Item 7: sampling independence | Item 8a: index test description | Item 8b: reference standard description | Item 9a: reference standard results(1) | Item 9b: reference standard results (2) | Item 10: interpretation | Item 11: uninterpretable/ intermediate test result | Item 12: withdrawal explanation | Total No. of Items = 14
Altuntas (1998) | yes | yes | yes | yes | yes | yes | yes | yes | yes | no | unclear | yes | yes | yes | 12 | (+) reported
Artan (1998) | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | yes | 13 | (+) reported
Ascher (1996) | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | unclear | yes | yes | yes | 12 | (+) reported
Ascher (1990) | yes | yes | yes | yes | yes | yes | yes | unclear | yes | unclear | unclear | yes | yes | yes | 11 | (+) reported
Bahia (2001) | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | unclear | yes | no | no | 10 | (+) reported
Bardella (2001) | yes | yes | yes | yes | yes | yes | yes | unclear | yes | unclear | unclear | yes | yes | yes | 11 | (+) reported
Berger (1996) | no | yes | yes | unclear | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | 12 | (+) reported
Biagi (2001) | no | unclear | yes | no | yes | yes | yes | yes | yes | no | unclear | yes | yes | yes | 9 | (+) reported
Bode (1993) | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | unclear | yes | yes | yes | 12 | (+) reported
Bonamico (2001) | no | unclear | yes | no | yes | yes | yes | yes | unclear | no | unclear | yes | yes | yes | 8 | (+) reported
Bottaro (1997) | no | no | yes | no | yes | yes | yes | unclear | yes | yes | unclear | yes | yes | yes | 9 | (+) reported
Carroccio (2002) | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | yes | 13 | (+) reported
Carroccio (1993) | no | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | yes | 12 | (+) reported
Carroccio (2002) | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | yes | 13 | (+) reported
Cataldo (2000) | no | yes | yes | unclear | yes | yes | yes | yes | yes | no | unclear | yes | yes | yes | 10 | (+) reported
Chan (2001) | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | yes | 13 | (+) reported
Chartrand (1997) | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | yes | 13 | (+) reported
Chirdo (1999) | yes | unclear | yes | yes | yes | yes | yes | yes | yes | no | unclear | yes | yes | yes | 11 | (+) reported
Chirdo (2000) | no | no | yes | yes | unclear | yes | yes | yes | yes | unclear | unclear | yes | yes | yes | 9 | (+) reported
Dahele (2001) | no | no | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | yes | 11 | (+) reported
Di Leo (1999) | no | unclear | yes | unclear | yes | yes | yes | yes | no | no | unclear | yes | yes | yes | 8 | (+) reported
Dickey (2001) | no | unclear | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | yes | 11 | (+) reported
Falth-Magnusson (1994) | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | unclear | yes | yes | no | 11 | (+) reported
Gillett (2000) | no | no | yes | yes | yes | no | yes | yes | yes | unclear | unclear | yes | yes | yes | 9 | (+) reported
Gonczi (1991) | yes | yes | yes | yes | no | yes | yes | yes | yes | no | unclear | yes | yes | yes | 11 | (+) reported
Hallstrom (1989) | no | no | yes | unclear | yes | yes | yes | yes | yes | unclear | unclear | yes | yes | yes | 9 | (+) reported
Hansson (2000) | no | no | yes | yes | yes | yes | yes | yes | yes | unclear | unclear | yes | yes | yes | 10 | (+) reported
Iltanen (1999) | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | unclear | yes | yes | yes | 12 | (+) reported
Kaukinen (2000) | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | yes | 13 | (+) reported
Kolho (1997) | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | 14 | (+) reported
Kumar (1989) | yes | yes | yes | yes | unclear | yes | yes | yes | yes | unclear | unclear | yes | yes | yes | 11 | (+) reported
Ladinser (1994) | no | no | yes | unclear | unclear | unclear | yes | yes | yes | unclear | unclear | yes | unclear | unclear | 5 | (+) reported
Lerner (1994) | no | yes | yes | yes | Yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | 13 | (+) reported
Lindberg (1985) | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | unclear | yes | yes | yes | 12 | (+) reported
Lindquist (1994) | yes | yes | yes | yes | yes | yes | yes | yes | yes | no | unclear | yes | yes | yes | 12 | (+) reported
Maki (1991) | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | yes | 13 | (+) reported
McMillan (1991) | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | 14 | (+) reported
Meini (1996) | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | unclear | yes | yes | yes | 12 | (+) reported
Pacht (1995) | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | yes | 13 | (+) reported
Picarelli (2000) | yes | unclear | yes | yes | yes | yes | yes | yes | yes | no | unclear | yes | yes | no | 10 | (+) reported
Poddar (2002) | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | unclear | 12 | (+) reported
Rich (1990) | yes | yes | yes | yes | yes | yes | yes | yes | yes | no | unclear | yes | yes | yes | 12 | (+) reported
Russo (1999) | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | yes | 13 | (+) reported
Salmaso (2001) | no | unclear | yes | unclear | unclear | unclear | yes | yes | no | unclear | unclear | yes | yes | yes | 6 | (+) reported
Sategna-Guidetti (1995) | no | unclear | yes | unclear | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | 11 | (+) reported
Sblattero (2000) | no | yes | yes | no | yes | no | yes | yes | yes | yes | unclear | yes | yes | yes | 10 | (+) reported
Sulkanen (1998) | no | yes | yes | yes | yes | yes | yes | yes | yes | unclear | unclear | yes | yes | yes | 11 | (+) reported
Tesei (2003) | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | yes | 13 | (+) reported
Troncone (1999) | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | unclear | yes | yes | yes | 12 | (+) reported
Valdimarsson (1996) | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | unclear | yes | yes | yes | 13 | (+) reported
Valentini (1994) | no | no | yes | yes | yes | yes | yes | yes | yes | unclear | unclear | yes | yes | yes | 10 | (+) reported
Vitoria (2001) | no | no | yes | no | yes | yes | yes | yes | no | no | unclear | yes | yes | yes | 8 | (+) reported
Vogelsang (1995) | yes | yes | yes | yes | yes | yes | yes | yes | yes | no | unclear | yes | yes | yes | 12 | (+) reported
Volta (1995) | no | unclear | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | yes | 12 | (+) reported
Whelan (1996) | no | unclear | yes | unclear | yes | yes | yes | yes | unclear | unclear | unclear | yes | yes | yes | 8 | (+) reported
Wolters (2002) | yes | no | yes | unclear | yes | yes | yes | yes | yes | no | unclear | yes | yes | yes | 10 | (+) reported
Item % (+) reported | 59% | 64% | 100% | 75% | 91% | 93% | 100% | 95% | 91% | 41% | 11% | 100% | 96% | 91%

(+) reported = postively reported; yes = reported; no = not reported

Table 2 Celiac 2 prevalence & incidence studies (cross-sectional checklist)

Author (Year) | Item 1: Source of Information | Item 2: Inclusion/Exclusion Criteria | Item 3: Time Period for Identity | Item 4: Subjects consecutive | Item 5: Evaluators Masked | Item 6: Quality Assurance Assessments | Item 7: Patient Exclusions | Item 8: Confounding assessed/controlled | Item 9: Missing Data | Item 10: Response Rates | Item 11: Follow-up | Total Items Reported (Max. 11)
Acerini (1998) | yes | No | yes | no | can't tell | no | no | no | yes | yes | yes | 5 | (+) reported
Ackerman (1996) | can't tell | no | yes | can't tell | no | no | no | no | no | yes | yes | 3 | (+) reported
Agardh (2001) | yes | can't tell | no | can't tell | no | no | yes | no | yes | can't tell | no | 3 | (+) reported
Aktay (2001) | yes | no | yes | no | no | no | no | no | no | no | no | 2 | (+) reported
Annibale (2001) | yes | yes | yes | yes | can't tell | can't tell | yes | no | no | yes | no | 6 | (+) reported
Annibale (2003) | yes | yes | yes | yes | no | no | yes | can't tell | no | yes | no | 6 | (+) reported
Arato (2002) | yes | yes | yes | yes | no | no | no | can't tell | no | can't tell | no | 4 | (+) reported
Bao (1999) | yes | no | no | can't tell | no | no | no | no | no | can't tell | no | 1 | (+) reported
Bardella (1991) | yes | no | no | yes | can't tell | yes | no | no | no | yes | no | 4 | (+) reported
Bardella (2001) | yes | no | yes | yes | no | no | no | no | no | yes | no | 4 | (+) reported
Barera (1991) | can't tell | no | yes | can't tell | no | no | no | no | no | yes | no | 2 | (+) reported
Barera (2002) | no | no | yes | yes | no | no | yes | no | no | can't tell | yes | 4 | (+) reported
Bode (1996) | yes | yes | yes | no | can't tell | no | yes | no | no | yes | no | 5 | (+) reported
Bode (1993) | yes | yes | yes | yes | no | yes | can't tell | yes | can't tell | yes | yes | 8 | (+) reported
Book (2003) | yes | can't tell | no | no | no | no | can't tell | no | no | no | can't tell | 1 | (+) reported
Borch (2000) | yes | no | no | no | no | no | yes | can't tell | no | yes | can't tell | 3 | (+) reported
Calero (1996) | yes | no | yes | yes | no | yes | yes | yes | no | no | no | 6 | (+) reported
Carlsson (2001) | yes | yes | yes | no | no | no | no | yes | no | yes | yes | 6 | (+) reported
Carroccio (2002) | can't tell | no | yes | yes | yes | no | yes | yes | no | yes | no | 6 | (+) reported
Catassi (1996) | yes | no | yes | can't tell | no | yes | no | yes | no | yes | no | 5 | (+) reported
Catassi (2000) | yes | yes | yes | no | no | no | yes | yes | no | yes | no | 6 | (+) reported
Chan (2001) | yes | yes | yes | can't tell | yes | no | can't tell | no | no | can't tell | no | 4 | (+) reported
Chartrand (1997) | yes | can't tell | yes | can't tell | no | can't tell | no | no | no | yes | no | 3 | (+) reported
Collin (2002) | yes | can't tell | yes | can't tell | no | no | yes | yes | no | can't tell | no | 4 | (+) reported
Collin (1997) | yes | yes | yes | no | no | no | no | yes | no | can't tell | no | 4 | (+) reported
Corazza (1997) | no | no | no | no | no | no | no | no | no | can't tell | no | 0 | (+) reported
Corazza (1995) | no | no | no | yes | no | no | no | no | no | yes | no | 2 | (+) reported
Corazza (1992) | no | no | no | can't tell | no | no | no | no | no | yes | no | 1 | (+) reported
Corrao (1996) | yes | can't tell | yes | no | can't tell | yes | yes | no | no | yes | no | 5 | (+) reported
Cronin (1997) | yes | no | no | yes | no | no | no | no | no | yes | no | 3 | (+) reported
Csizmadia (1999) | yes | can't tell | yes | no | can't tell | no | can't tell | no | no | yes | yes | 4 | (+) reported
Day (2000) | yes | yes | yes | no | can't tell | no | yes | no | no | no | no | 4 | (+) reported
De Block (2001) | yes | no | no | can't tell | no | no | no | no | no | can't tell | no | 1 | (+) reported
De, Vitis (1996) | no | no | no | no | no | no | no | no | no | yes | no | 1 | (+) reported
Dickey (1997) | no | can't tell | no | can't tell | no | no | no | can't tell | no | yes | no | 1 | (+) reported
Dickey (1992) | yes | yes | no | can't tell | no | no | no | no | yes | no | no | 3 | (+) reported
Farre (1999) | yes | yes | yes | can't tell | no | no | no | yes | no | yes | no | 5 | (+) reported
Fasano (2003) | yes | yes | yes | can't tell | no | no | no | yes | no | yes | yes | 6 | (+) reported
Fitzpatrick (2001) | yes | can't tell | no | can't tell | no | no | yes | no | no | yes | no | 3 | (+) reported
Fraser-Rey0lds (1998) | can't tell | can't tell | yes | no | no | no | no | yes | no | yes | yes | 4 | (+) reported
Gillett (2001) | yes | can't tell | yes | no | yes | no | no | yes | no | yes | no | 5 | (+) reported
Gonzalez (2002) | can't tell | can't tell | no | yes | yes | no | can't tell | yes | no | yes | no | 4 | (+) reported
Green (2000) | yes | no | yes | yes | yes | yes | no | can't tell | no | yes | yes | 7 | (+) reported
Grodzinsky (1996) | yes | no | yes | no | no | yes | no | no | no | no | no | 3 | (+) reported
Hansen (2001) | no | can't tell | no | yes | no | no | no | no | no | no | no | 1 | (+) reported
Hawkes (2000) | yes | can't tell | yes | no | no | no | no | no | no | no | no | 2 | (+) reported
Hill (2000) | yes | no | no | no | no | no | no | yes | no | yes | yes | 4 | (+) reported
Hin (1999) | yes | yes | yes | yes | can't tell | yes | no | can't tell | no | yes | no | 6 | (+) reported
Hoffenberg (2003) | yes | yes | yes | can't tell | yes | no | can't tell | yes | no | yes | yes | 7 | (+) reported
Hogberg (2003) | yes | no | yes | no | no | no | can't tell | no | no | yes | yes | 4 | (+) reported
Holm (1993) | can't tell | no | no | can't tell | no | no | no | can't tell | no | yes | no | 1 | (+) reported
Hovdenak (1999) | no | no | no | no | no | no | no | no | no | yes | no | 1 | (+) reported
Howard (2002) | yes | yes | yes | can't tell | can't tell | no | yes | no | no | yes | no | 5 | (+) reported
Ivarsson (1999) | yes | can't tell | yes | yes | no | no | no | yes | no | yes | no | 5 | (+) reported
Ivarsson (2003) | yes | yes | yes | yes | no | no | no | yes | no | yes | no | 6 | (+) reported
Jaeger (2001) | no | can't tell | no | no | no | no | no | can't tell | no | yes | no | 1 | (+) reported
Jansen Th (1993) | yes | yes | yes | no | no | can't tell | no | no | no | yes | no | 4 | (+) reported
Johnston (1998) | yes | can't tell | can't tell | can't tell | yes | no | yes | no | can't tell | yes | yes | 5 | (+) reported
Kaukinen (1999) | can't tell | no | yes | can't tell | no | no | no | no | no | yes | no | 2 | (+) reported
Kepczyk (1995) | yes | yes | yes | yes | can't tell | yes | no | can't tell | no | yes | yes | 7 | (+) reported
Kolho (1998) | yes | can't tell | yes | can't tell | no | no | no | no | no | yes | yes | 4 | (+) reported
Kordonouri (2000) | no | no | no | no | no | no | yes | no | no | yes | no | 2 | (+) reported
Kotze (2001) | yes | no | no | no | can't tell | no | no | can't tell | can't tell | yes | no | 2 | (+) reported
Lampasona (1999) | no | no | no | no | no | no | no | no | no | can't tell | no | 0 | (+) reported
Li Voon Chong (2002) | no | no | yes | no | no | no | no | yes | no | can't tell | no | 2 | (+) reported
Lindh (1992) | no | no | no | yes | no | no | no | no | no | yes | no | 2 | (+) reported
Lopez-Rodriguez (2003) | yes | can't tell | yes | yes | no | yes | no | no | no | yes | no | 5 | (+) reported
Lorini (1996) | no | no | no | no | no | yes | no | no | no | yes | no | 2 | (+) reported
Magazzu (1994) | yes | can't tell | yes | no | can't tell | no | no | no | no | yes | no | 3 | (+) reported
Maki (1988) | yes | no | yes | yes | can't tell | no | no | no | no | no | no | 3 | (+) reported
Maki (2003) | yes | can't tell | yes | can't tell | no | no | yes | yes | no | yes | no | 5 | (+) reported
Mather (2001) | no | no | no | yes | no | no | can't tell | no | yes | yes | no | 3 | (+) reported
Mazzetti (1992) | yes | yes | no | no | no | no | no | no | no | no | no | 2 | (+) reported
McIntyre (1993) | yes | no | yes | yes | no | no | yes | no | no | yes | yes | 6 | (+) reported
Mustalahti (2002) | no | can't tell | no | can't tell | no | yes | yes | no | no | yes | no | 3 | (+) reported
Ot (1998) | can't tell | no | no | no | can't tell | no | no | yes | no | can't tell | no | 1 | (+) reported
Ot (2001) | yes | no | yes | yes | no | no | no | no | no | yes | no | 4 | (+) reported
Nuti (2001) | yes | yes | yes | yes | can't tell | yes | can't tell | no | can't tell | yes | yes | 7 | (+) reported
Oxentenko (2002) | yes | can't tell | yes | no | no | no | yes | can't tell | no | yes | no | 4 | (+) reported
Page (1994) | yes | Yes | yes | yes | yes | no | yes | yes | no | no | yes | 8 | (+) reported
Pittschieler (1996) | yes | no | no | no | no | no | no | no | no | no | no | 1 | (+) reported
Pittschieler (2003) | yes | can't tell | yes | can't tell | no | no | can't tell | can't tell | no | can't tell | yes | 3 | (+) reported
Polvi (1996) | yes | yes | no | yes | no | no | yes | no | yes | yes | yes | 7 | (+) reported
Ransford (2002) | no | no | no | yes | no | no | yes | no | no | yes | no | 3 | (+) reported
Rensch (1996) | yes | yes | yes | yes | can't tell | yes | yes | no | yes | yes | no | 8 | (+) reported
Riestra (2000) | can't tell | can't tell | yes | no | no | yes | no | yes | no | yes | no | 4 | (+) reported
Robinson (1971) | yes | no | no | yes | no | no | no | no | no | no | no | 2 | (+) reported
Roldan (1998) | yes | no | yes | no | no | yes | no | no | no | no | no | 3 | (+) reported
Rolles (1974) | yes | yes | no | no | no | no | no | no | no | yes | can't tell | 3 | (+) reported
Rossi (1993) | yes | can't tell | yes | no | no | no | no | no | no | yes | no | 3 | (+) reported
Rostami (2000) | no | no | no | no | yes | no | no | no | no | yes | no | 2 | (+) reported
Rostami (1999) | yes | no | yes | no | no | no | no | no | no | yes | no | 3 | (+) reported
Rutz (2002) | can't tell | no | no | no | no | yes | no | yes | no | yes | yes | 4 | (+) reported
Sanders (2003) | yes | no | yes | no | no | no | no | yes | no | yes | yes | 5 | (+) reported
Sategna-Guidetti (1994) | yes | no | no | no | no | no | no | no | no | yes | no | 2 | (+) reported
Saukkonen (1996) | yes | no | yes | yes | no | yes | yes | can't tell | no | yes | yes | 7 | (+) reported
Schober (2000) | yes | no | no | no | no | no | no | yes | no | no | no | 2 | (+) reported
Sigurs (1993) | yes | yes | yes | no | no | no | yes | no | no | yes | no | 5 | (+) reported
Sjoberg (1999) | yes | can't tell | yes | yes | can't tell | no | can't tell | yes | no | yes | no | 5 | (+) reported
Sjoberg (1994) | yes | can't tell | yes | yes | no | no | yes | no | no | yes | no | 5 | (+) reported
Sjoberg (1998) | yes | no | yes | no | no | yes | yes | no | no | yes | no | 5 | (+) reported
Spiekerkoetter (2002) | no | no | yes | can't tell | can't tell | no | no | no | no | yes | yes | 3 | (+) reported
Stokes (1976) | yes | no | no | can't tell | no | no | can't tell | yes | no | yes | yes | 4 | (+) reported
Talal (1997) | no | yes | no | can't tell | no | no | yes | yes | no | yes | yes | 5 | (+) reported
Talley (1994) | yes | yes | yes | no | no | can't tell | yes | yes | no | yes | no | 6 | (+) reported
Thomas (1992) | yes | no | yes | can't tell | can't tell | can't tell | no | no | no | yes | no | 3 | (+) reported
Trevisiol (1999) | yes | can't tell | yes | can't tell | no | no | no | no | no | no | yes | 3 | (+) reported
Tursi (2003) | no | no | no | can't tell | yes | no | no | no | no | no | no | 1 | (+) reported
Unsworth (2000) | yes | can't tell | yes | can't tell | no | no | no | yes | no | yes | yes | 5 | (+) reported
Valerio (2002) | yes | can't tell | yes | can't tell | no | no | no | no | no | yes | no | 3 | (+) reported
Van Mook (2001) | yes | yes | no | no | can't tell | no | yes | no | no | yes | no | 4 | (+) reported
Ventura (2001) | can't tell | yes | can't tell | can't tell | no | no | yes | can't tell | no | yes | no | 3 | (+) reported
Vitoria (1994) | no | can't tell | no | can't tell | no | no | can't tell | no | no | can't tell | no | 0 | (+) reported
Vitoria (1998) | yes | no | no | no | no | no | no | no | no | no | yes | 2 | (+) reported
Volta (2001) | can't tell | yes | yes | no | no | no | no | no | no | yes | no | 3 | (+) reported
Weile (1993) | yes | yes | yes | no | no | no | no | no | no | yes | no | 4 | (+) reported
Weile (2001) | yes | no | no | yes | no | no | no | yes | no | yes | no | 4 | (+) reported
West (2003) | yes | can't tell | yes | no | no | no | yes | yes | no | yes | no | 5 | (+) reported
% Items (+) reported: | 71% | 27% | 60% | 29% | 8% | 16% | 28% | 27% | 5% | 73% | 25%

Table 3 Celiac 3 cohort studies (Ottawa-Newcastle Scale)

Author (Year) | Item 1: selection of exposed | Item 2: selection of non-exposed | Item 3: ascertainment of exposure | Item 4: outcome missing data at initiation | Item 5: control factors (2*'s) | Item 6: assessment of outcome | Item 7: adequacy of follow-up length | Item 8: accountability for follow-up
Askling (2002) | 1 | 1 | 1 | 1 | 2 | 1 | 1 | 1 | 9 (*) awarded
Collin (1996) | 1 | 1 | 1 | 1 | 2 | 1 | 1 | 0 | 8 (*) awarded
Corrao (2001) | 1 | 1 | 1 | 0 | 2 | 1 | 1 | 1 | 8 (*) awarded
Cottone (1999) | 1 | 1 | 1 | 1 | 2 | 1 | 1 | 1 | 9 (*) awarded
Green (2003) | 1 | 1 | 1 | 1 | 2 | 1 | 1 | 0 | 8 (*) awarded
Holmes (1989) | 1 | 1 | 1 | 1 | 2 | 1 | 1 | 1 | 9 (*) awarded
Logan (1989) | 1 | 1 | 1 | 0 | 2 | 1 | 1 | 1 | 8 (*) awarded
Nielsen (1985) | 1 | 1 | 1 | 1 | 2 | 1 | 1 | 0 | 8 (*) awarded
Selby (1979) | 1 | 1 | 1 | 1 | 2 | 1 | 1 | 0 | 8 (*) awarded
Item % (+) reported | 100% | 100% | 100% | 78% | 100% | 100% | 100% | 56%

a maximum of 9 stars* may be awarded per study

Table 4 Celiac 3 case-control study (Ottawa-Newcastle Scale)

Author (Year) | Item 1: case definition | Item 2: representativeness of cases | Item 3: selection of controls | Item 4: definition of controls | Item 5: control factors | Item 6: ascertainment of exposure | Item 7: method of ascertainment for cases and controls | Item 8: non-response rate
Delco (1999) | 1 | 1 | 1 | 1 | 2 | 0 | 1 | 0 | 7 (*) awarded

a maximum of 9 stars* may be awarded per study

Table 5 Celiac 4 cohort studies (Ottawa-Newcastle Scale)

Author (Year) | Item 1: selection of exposed | Item 2: selection of non-exposed | Item 3: ascertainment of exposure | Item 4: outcome missing data at initiation | Item 5: control factors (2*'s) | Item 6: assessment of outcome | Item 7: adequacy of follow-up length | Item 8: accountability for follow-up
Amin (2002) | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 0 | 5 (*) awarded
Greco (1997) | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 0 | 5 (*) awarded
Harewood (2001) | 1 | 1 | 0 | 0 | 1 | 0 | 1 | 1 | 5 (*) awarded
Holmes (1976) | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 6 (*) awarded
Johnston (1998) | 1 | 1 | 1 | 1 | 2 | 1 | 0 | 1 | 8 (*) awarded
Poddar (2002) | 1 | 1 | 1 | 1 | 0 | 0 | 1 | 0 | 5 (*) awarded
Item % (+) reported | 100% | 100% | 70% | 50% | 50% | 33% | 83% | 33%

a maximum of 9 stars* may be awarded per study

Table 6 Celiac 4 case-control study (Ottawa-Newcastle Scale)

Author (Year) | Item 1: case definition | Item 2: representativeness of cases | Item 3: selection of controls | Item 4: definition of controls | Item 5: control factors (2*'s) | Item 6: ascertainment of exposure | Item 7: method of ascertainment for cases and controls | Item 8: non-response rate
Ciacci (1996) | 1 | 0 | 1 | 1 | 0 | 1 | 1 | 0 | 4 (*) awarded
Fabiani (1996) | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 0 | 7 (*) awarded
Thomason (2003) | 1 | 0 | 1 | 1 | 2 | 0 | 1 | 1 | 6 (*) awarded
Westman (1999) | 1 | 0 | 1 | 1 | 2 | 0 | 1 | 0 | 5 (*) awarded
Item % (+) reported | 100% | 25% | 100% | 100% | 62.5% | 50% | 100% | 25%

a maximum of 9 star* may be awarded per study

Table 7 Celiac 4—Quality assessment not applicable to those studies identified as ‘Other’ in design

Author (Year)
Annibale (2001)
Arato (2002)
Atkinson (1997)
Bai (1997)
Bardella (2000)
Bardella (1985)
Barera (2000)
Boersma (2002)
Corrao (2001)
Fabiani (2000)
Kemppainen (1999)
Kemppainen(1998)
Mora (2001)
Mustalahti (1999)
Rea (1996)
Sategna-Guidetti (2000)
Sategna-Guidetti (2001)
Saukkonen (2002)
Valdimarsson (2000)
Zaccari (1996)

Table 8 Celiac 4—Quality assessment pending

Author (Year)
Smecuol (1997)
Valdimarsson (1996)

Table 9 Celiac 5 case-control studies (Ottawa-Newcastle Scale)

Author (Year) | Item 1: case definition | Item 2: representativeness of cases | Item 3: selection of controls | Item 4: definition of controls | Item 5: control factors (2*'s) | Item 6: ascertainment of exposure | Item 7: method of ascertainment for cases and controls | Item 8: Non-response rate
Bardella (2001) | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 8 (*) awarded
Fabiani (2001) | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 1 | 6 (*) awarded
Anson (1990) | 1 | 1 | 1 | 0 | 1 | 0 | 1 | 1 | 6 (*) awarded
Fabiani (2000) | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 7 (*) awarded
Item % (+) reported | 100% | 100% | 100% | 50% | 50% | 25% | 100% | 100%

a maximum of 9 stars* may be awarded per study

Table 10 Celiac 5 cohort studies (Ottawa-Newcastle Scale)

Author (Year) | Item 1: Selection of exposed | Item 2: selection of non-exposed | Item 3: ascertainment of exposure | Item 4: outcome missing data at initiation | Item 5: control factors (2*'s) | Item 6: assessment of outcome | Item 7: adequacy of follow-up length | Item 8: accountability for follow-up
McNicholl (1976) | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 6 (*) awarded
Pacht (1995) | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 1 | 6 (*) awarded
Sategna-Guidetti (1996) | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 1 | 7 (*) awarded
Troncone (1995) | 1 | 1 | 1 | 0 | 0 | 1 | 1 | 1 | 6 (*) awarded
Hogberg (2003) | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 1 | 8 (*) awarded
Fabiani (1996) | 1 | 1 | 1 | 1 | 1 | 0 | 1 | 1 | 7 (*) awarded
Item % (+) reported | 83% | 100% | 83% | 50% | 33% | 83% | 100% | 100%

a maximum of 9 stars* may be awarded per study

Table 11 Celiac 5 non-comparative case series checklist

Author (Year) | Item 1: Intervention | Item 2: Inclusion/exclusion criteria | Item 3: follow-up as an inclusion | Item 4: sample size determination | Irem 5: sample size calculations | Item 6: method & length/accumulation of cases | Item 7: sources of participants | Item 8: method of outcome assessments | Item: 9: blinding | Item 9: primary and secondary measures | Item 11: timing of outcome assessment | Item 12: follow-up schedule | Item 13: maintaining follow-up | Item 14: compliance with follow-up | Item 15: method of data collection | Item 16: exclusions | Item 17: statistical approach for analysis | Item 18: missing data | Item 19: adverse events | Total # of Items = 19
Burgin-Wolff (1991) | Yes | yes | no | can' tell | no | no | yes | yes | no | yes | can' tell | can' tell | yes | yes | yes | can' tell | yes | no | no | 9 | (+) reported
Burgin-Wolff (2002) | yes | yes | can' tell | can' tell | no | no | yes | yes | no | yes | yes | yes | no | no | yes | no | yes | can' tell | no | 9 | (+) reported
Dickey (2000) | yes | yes | no | yes | no | yes | yes | yes | no | yes | yes | yes | can' tell | yes | yes | yes | yes | yes | no | 14 | (+) reported
Fotoulaki (1999) | yes | yes | no | yes | no | yes | yes | Yes | no | yes | Yes | yes | no | no | yes | no | yes | no | no | 11 | (+) reported
Kaukinen (2002) | yes | yes | no | yes | no | no | no | yes | no | yes | yes | yes | no | no | yes | no | yes | no | no | 9 | (+) reported
Lee (2003) | yes | yes | no | yes | no | yes | yes | yes | no | yes | yes | yes | can' tell | yes | yes | yes | yes | yes | no | 14 | (+) reported
Martini (2002) | yes | yes | no | yes | no | yes | yes | yes | no | yes | yes | yes | can' tell | no | yes | no | yes | no | no | 11 | (+) reported
Scalici (2003) | yes | yes | can' tell | can' tell | no | no | can' tell | can' tell | yes | yes | yes | yes | can' tell | can' tell | yes | can' tell | yes | no | no | 8 | (+) reported
Selby (1999) | yes | yes | no | yes | no | yes | yes | yes | no | yes | yes | yes | can' tell | yes | yes | can' tell | yes | no | no | 12 | (+) reported
Valentini (1994) | yes | yes | no | no | no | no | can' tell | yes | no | yes | yes | yes | no | no | yes | no | yes | no | no | 7 | (+) reported
Valletta (1990) | yes | yes | no | no | no | no | no | yes | no | yes | yes | yes | can' tell | no | yes | no | yes | no | no | 8 | (+) reported
% of items (+) reported | 100% | 100% | 0% | 55% | 0% | 45% | 64% | 91% | 9% | 100% | 91% | 91% | 9% | 36% | 100% | 18% | 100% | 18% | 0%

yes =reported; no=not reported

Table 12 Celiac 5—Quality assessment not applicable to the following study designs

Author (Year) | Study type
Jackson (1985) | questionnaire
Lamontagne (2001) | questionnaire
Ljungman (1993) | questionnaire
Vahedi (2000) | abstract

Table 13 Celiac 5—Quality assessment pending

Author (Year)
Baker (1975)
Bartholomeusz (1990)
Ciacci (2002)
Ciacci (2002)
Fabiani (1996)
Hogberg (2003)
Johnston (1998)
Kotze (2001)
Mayer (1991)
Skerritt (1991)
Vahedi (2003)
Volta (1990)