# Appendix A

Table 1 Various causes of villous atrophy (VA; Farrell and Kelly, Am J Gastro 2001;96:3237)

Celiac disease
Dermatitis herpetiformis
Cow's milk protein intolerance (children)
Post-gastroenteritis
Giardiasis
Peptic duodenitis
Crohn's disease
Small intestinal bacterial overgrowth
Eosinophilic gastroenteritis
Radiation or chemotherapy
Tropical sprue
Severe malnutrition
Diffuse small intestinal lymphoma
Graft versus host disease
Hypogammaglobulinemia
Alpha chain disease

Table 2 Marsh (Gastroenterology 1992;102:330) and Rostami (Am J Gastroenterol 1999;94:888) modified histological criteria for CD

Criteria | | Rostami modification (1999) | Original Marsh (1992)
Marsh 0 | | Same as original | Pre-infiltrative:
| | | • Normal mucosal and villous architecture
Marsh I | | Same as original | Infiltrative:
| | | • Normal mucosal and villous architecture
| | | • Increased numbers of IELs
Marsh II | | Same as original | Hyperplastic:
| | | • Similar to above but with enlarged crypts, with increased crypt cell division
Marsh III | a | Partial VA: | Destructive lesion:
| | • Shortened blunt villi | • Flat mucosa - complete loss of villi
| | • Mild lymphocyte infiltration | • Lymphocyte infiltration
| | • Enlarged hyperplastic crypts | • Enlarged hyperplastic crypts
| b | Sub-total VA:
| | • Clearly atrophic villi - but still recognizable
| | • Enlarged crypts whose immature epithelial cells are generated at an increased rate
| | • Influx of inflammatory cells
| c | Total VA:
| | • Nearly total VA
| | • Severe Marsh atrophic, hyperplastic and infiltrative lesions
Marsh IV | | Same as original | Hypoplastic:
| | | • Total VA
| | | • Normal crypt height but hypoplasia
| | | • Normal IEL count
| | | • Many feel this doesn't exist and represents severe malnutrition

VA=villous atrophy

IEL=intraepithelial lymphocytes

Table 3 Revised ESPGAN criteria

Criteria | ESPGAN*- 1979 | ESPGAN^†^- Revised 1990
Initial histology | - Absent or nearly absent villi | - Biopsy must remain the initial step in the diagnosis (mandatory)
| - Recognized existence of less severe lesion | - Recommend capsule over endoscopic biopsy
| - No consensus on verification of less severe lesions but recommended if possible continuing gluten diet and assess histology, or re-challenge after GFD, given the large differential of milder histologic lesions | - Large well oriented biopsy
| | - Histology: hyperplastic VA with hyperplasia of the crypts and an abnormal surface epithelium. The IEL count is raised
| | - Morphometery and histochemistry are important aids to diagnosis.
| | - Monoclonal antibodies to IEL may be a future aid
Antibody studies | - n/a | - Recognize that IgA AGA, and EMA have a high degree of sensitivity and specificity for the diagnosis of CD
| | - When such antibodies are present at the time of diagnosis in a child with a typical small intestinal mucosa, and when they disappear in parallel to a clinical response to a GFD, weight is added to the diagnosis of CD that may now be said to have been finally established
| | - When biopsy is unavailable in communities were other causes of enteropathy are rare, the presence of abnormal concentrations of two antibodies strongly suggests that CD is a diagnostic possibility
| | - Antibodies can be a marker of response to a GFD and a guide to dietary compliance
Improvement on GFD | - Recognized as central to the definition | - Second mandatory requirement remains a reasonably rapid (weeks rather than many months) clinical remission on a strict GFD
| - Recognized that improvement need not be complete | - Control biopsy is always a suitable way of verifying the effect of GFD, and is required in asymptomatic pts
Gluten Challenge | - Importance of gluten challenge and re-biopsy emphasized to document “permanence” of gluten intolerance | - No longer a requirement
| - However, the panel recognized that challenge was not being performed in routine practice (only 652 were performed among several thousand children with gluten intolerance) | - Should be used in equivocal cases such as when no initial biopsy was done, biopsy was inadequate or atypical, in communities with high rates of other enteropathies, or in situations when pts plan to abandon the GFD in an uncontrolled way
| | - Challenge should be performed after obtaining a control biopsy on a GFD
| | - Re-biopsy is performed 3–6 months later with the recognition that relapse can take 5–7 years or more to occur.
2-year rule | - To address the issue of transient gluten intolerance, the panel emphasized the usefulness of the 2-year rule after stopping a GFD | - The 2-year rule is practical in most cases, but several reports of relapse occurring 5–7 years after gluten rechallenge
| - 619 of 652 gluten challenges redeveloped histology compatible with CD by 2 years

* McNeish et al., Arch Dis Child 1979;54:783

† Walker-Smith et al., Arch Dis Child 1990:65:99

CD=celiac disease; n/a=not applicable; GFD=gluten-free diet