# Appendixes

Appendix A

Appendix B. Search Strategies

Appendix C. Data Assessment and Data Abstraction Forms

Appendix D. Quality Assessment Forms

Appendix E. Summary ROC Curves

Appendix F. Modified QUOROM Flow Chart

Appendix G. Raw Pooled Data

Appendix H. Biopsy Results

Appendix I. Evidence Tables

Appendix J. Quality Assessment

Appendix K. Additional Acknowledgements

Appendix L. Listing of Excluded Studies