# Reference List

1 Bray G A, Greenway F L. Current and potential drugs for treatment of obesity. Endor Rev. 1999;20(6):805-75.
2 Flegal K M, Carroll M D, Ogden C L, et al. Prevalence and trends in obesity among US adults, 1999-2000. JAMA. 2002;288(14):1723-7. [pmid: 12365955].
3 Mokdad A H, Bowman B A, Ford E S, et al. The continuing epidemics of obesity and diabetes in the United States. JAMA. 2001;286(10):1195-200. [pmid: 11559264].
4 Mokdad A H, Serdula M K, Dietz W H, et al. The continuing epidemic of obesity in the United States. JAMA. 2000;284(13):1650-1. [pmid: 11015792].
5 Mokdad A H, Serdula M K, Dietz W H, et al. The spread of the obesity epidemic in the United States, 1991-1998. JAMA. 1999;282(16):1519-22. [pmid: 10546690].
6 Centers for Disease Control and Prevention. Obesity epidemic increases dramatically in the United States. available at URL: http://www.cdc.gov/nccdphp/dnpa/obesityepidemichim. Accessed 6/11/2002.
7 Kuczmarski R J, Flegal K M, Campbell S M, et al. Increasing prevalence of overweight among US adults. The National Health and Nutrition Examination Surveys, 1960 to 1991. JAMA. 1994;272(3):205-11. [pmid: 8022039].
8 Katzmarzyk P T. The Canadian obesity epidemic, 1985-1998. CMAI. 2002;166(8):1039-40.
9 Katzmarzyk P. T. Obesity in Canadian children. CMAJ 2001;164(11):1563–4; author reply 1564–5.
10 World Health Organization. Controlling the global obesity epidemic. available at URL: http://www.who.int/nut/obs.html. Accessed 6/20/2002.
11 Friedrich M J. Epidemic of obesity expands its spread to developing countries. JAMA. 2002;287(11):1382-6. [pmid: 11903011].
12 Must A, Spadano J, Coakley E H, et al. The disease burden associated with overweight and obesity. JAMA. 1999;282(16):1523-9. [pmid: 10546691].
13 Pi-Sunyer F X. Medical hazards of obesity. Ann Intern Med. 1993;119(7 Pt 2):655-60. [pmid: 8363192].
14 Ogden C L, Flegal K M, Carroll M D, et al. Prevalence and trends in overweight among US children and adolescents, 1999-2000. JAMA. 2002;288(14):1728-32. [pmid: 12365956].
15 Eckel R H, Krauss R M. American Heart Association call to action: obesity as a major risk factor for coronary heart disease. AHA Nutrition Committee. Circulation. 1998;97(21):2099-100. [pmid: 9626167].
16 National Institutes of Health. Clinical Guidelines on the Identification, Evaluation, and Treatment of Overweight and Obesity in Adults--The Evidence Report. Obes Res. 1998;6 Suppl 2:51S-209S. [pmid: 9813653].
17 Pi-Sunyer FX. A review of long-term studies evaluating the efficacy of weight loss in ameliorating disorders associated with obesity. Clin Ther 1996;18(6):1006–35; discussion 1005.
18 Allison D B, Pi-Sunyer F X. Obesity treatment: examining the premises. Endocr Pract. 1995;1:353-364. [pmid: 15251583].
19 Calle E E, Rodriguez C, Walker-Thurmond K, et al. Overweight, obesity, and mortality from cancer in a prospectively studied cohort of U.S. adults. N Engl J Med. 2003;348(17):1625-38. [pmid: 12711737].
20 Huang Z, Hankinson S E, Colditz G A, et al. Dual effects of weight and weight gain on breast cancer risk. JAMA. 1997;278(17):1407-11. [pmid: 9355998].
21 Goldstein D J. Beneficial health effects of modest weight loss. Int J Obes Relat Metab Disord. 1992;16(6):397-415. [pmid: 1322866].
22 Knowler W C, Barrett-Connor E, Fowler S E, et al. Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002;346(6):393-403. [pmid: 11832527]. [pmcid: 1370926].
23 National Library of Medicine/National Institutes of Health. Sibutramine. Medline Plus Drug Information. available at URL: http://www.nlm.nih.gov/medlineplus/druginfo/medmaster/a697012.html. Accessed 5/14/2004.
24 Croghan, T. Personal Communication, Washington DC, RAND. 2004.
25 National Library of Medicine/ National Institutes of Health. Sertraline. Mediline Plus Drug Information. available at URL: http://www.nlm.nih.gov/medlineplus/druginfo/medmaster/a697048.html.Accessed 5/4/2004.
26 Nielsen J A, Chapin D S, Johnson J L Jr, et al. Sertraline, a serotonin-uptake inhibitor, reduces food intake and body weight in lean rats and genetically obese mice. Am J Clin Nutr. 1992;55 (1 Suppl):185S-189S. [pmid: 1442668].
27 History of Phentermine. Phentermine. available at URL: http://www.phentermine.com/phentermine_history.htm. Accessed 5/4/2004.
28 RxList.com. Tenuate (Diethylpropion) Description. available at URL: http://www.rxlist.com/cgi/generic3/diethprop.htm.Accessed 5/4/2004.
29 Thompson CenterWatch Clinical Trials Listing Service. Drugs Approved by the FDA: Drug Name Zonegrin (Zonisamide) Capsules. available at URL: http://www.centerwatch.com/patient/drugs/dru613.html. Accessed 5/4/2004.
30 Woods T M, Eichner S F, Franks A S. Weight gain mitigation with topiramate in mood disorders. Ann Pharmacother. 2004;38(5):887-91. [pmid: 15039481].
31 Bray G A, Hollander P, Klein S, et al. A 6-Month Randomized, Placebo-Controlled, Dose-Ranging Trial of Topiramate for Weight Loss in Obesity. Obes Res. 2003;11(6):722-733. [pmid: 12805393].
32 National Library of Medicine/National Institutes of Health. Topiramate. Medline Plus Drug Information. available at URL: http://www.nlm.nih.gov/medlineplus/druginfo/medmaster/a697012.html.Accessed 5/14/2004.
33 Roche Pharmaceuticals Complete Product Information. Xenical (orlistat). available at URL: http://www.rocheusa.com/products/xenical/. Accessed 5/14/2004.
34 Avenell A,Broom J, Aucott L, Brown TJ, Poobalan A, Stearns S, et al. Systematic review of the long-term outcomes of the treatments for obesity and implications for health improvement and the economic consequences for the National Health Service. Health Technol Assess 2003 (In Press).
35 O'Meara S, Riemsma R, Shirran L, et al. A rapid and systematic review of the lcinical effectiveness and cost-effectiveness of orlistat in the management of obesity. Health Technol Assess. 2001;5(18):1-81. [pmid: 11701100].
36 Arterburn DE, Crane PK, Veenstra DL. The efficacy and safety of sibutramine for weight loss: A systematic review. (In Press).
37 Clegg A, Colquitt J, Sidhu MK, Royle P, Loveman E, Walker A. The clinical effectiveness and cost-effectiveness of surgery for people with morbid obesity: a systematic review and economic evaluation. Health Technol Assess 2002;6(12).
38 Colquitt J, Clegg A, Sidhu M, et al. Surgery for morbid obesity (Cochrane Review). Cochrane Database Syst Rev 2003;(2):CD003641.
39 Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
40 Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. 1998;352(9128):609-613. [pmid: 9746022].
41 Stata Statistical Software: Release 7.0 [computer program]. Version 7.0. College Station: Stata Corporation; 2001.
42 Sutton A J, Jones D R, Abrams K R, et al. Systematic reviews and meta-analysis: a structured review of the methodological literature. J Health Serv Res Policy. 1999;4(1):49-55. [pmid: 10345567].
43 Anderson J W, Greenway F L, Fujioka K, et al. Bupropion SR enhances weight loss: a 48-week double-blind, placebo- controlled trial. Obes Res. 2002;10(7):633-41. [pmid: 12105285].
44 Michelson D, Amsterdam JD, Kim Y, Sundell K. Changes in weight during a one-year trial with fluoxetine. 152nd Annual Meeting of the American Psychiatric Association. May 15th – 20th, 1999; Washington, DC, USA. 1999.
45 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-188. [pmid: 3802833].
46 Hedges LV, Olkin I. Statistical methods for meta-analysis. San Diego, CA: Academic Press, Inc.; 1985.
47 Egger M, Davey Smith G, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629-634. [pmid: 9310563]. [pmcid: 2127453].
48 Begg C B, Mazumdar M. Operating characteristics of a rank correlation test for publication bias. Biometrics. 1994;50(4):1088-1101. [pmid: 7786990].
49 StatXact 4 for Windows [computer program]. Version 4.0. Cambridge, MA: Cytel Software Corporation; 2000.
50 Miller J.N., Colditz G.A., Mosteller F. How study design affects outcomes of comparisons of therapy: II: surgical. Stats Med. 1989 8:455–466.(Abstract)
51 Moseley J., O'Malley K., Petersen N.J., Brody B.A., Kuykendall D.H., Hollingsworth J.C., et al. A controlled trial of arthroscropic surgery for osteoarthritis of the knee. J Fam Pract. 2002 51:(10)813-(Abstract)
52 Failure of extracranial-intracranial arterial bypass to reduce the risk of ischemic stroke. Results of an international randomized trial. The EC/IC Bypass Study Group. N Engl J Med. 1985 313:(19)1191–200.(Abstract)
53 Arterburn D E, Crane P K, Veenstra D L. The efficacy and safety of sibutramine for weight loss: a systematic review. Arch Intern Med. 2004;164(9):994-1003. [pmid: 15136309].
54 Bray G A, Blackburn G L, Ferguson J M, et al. Sibutramine produces dose-related weight loss. Obes Res. 1999;7(2):189-98. [pmid: 10102256].
55 Davidson M H, Hauptman J, DiGirolamo M, et al. Weight control and risk factor reduction in obese subjects treated for 2 years with orlistat: a randomized controlled trial. JAMA. 1999;281(3):235-42. [pmid: 9918478].
56 Hauptman J, Lucas C, Boldrin M N, et al. Orlistat in the long-term treatment of obesity in primary care settings. Arch Fam Med. 2000;9(2):160-7. [pmid: 10693734].
57 Hill J O, Hauptman J, Anderson J W, et al. Orlistat, a lipase inhibitor, for weight maintenance after conventional dieting: a 1-y study. Am J Clin Nutr. 1999;69(6):1108-16. [pmid: 10357727].
58 Hollander P A, Elbein S C, Hirsch I B, et al. Role of orlistat in the treatment of obese patients with type 2 diabetes. A 1-year randomized double-blind study. Diabetes Care. 1998;21(8):1288-94. [pmid: 9702435].
59 Lindahl B, Dinesen B, Eliasson M, et al. High proinsulin concentration precedes acute myocardial infarction in a nondiabetic population. Metabolism. 1999;48(9):1197-202. [pmid: 10484064].
60 Rossner S, Sjostrom L, Noack R, et al. Weight loss, weight maintenance, and improved cardiovascular risk factors after 2 years treatment with orlistat for obesity. European Orlistat Obesity Study Group. Obes Res. 2000;8(1):49-61. [pmid: 10678259].
61 Sjostrom L, Rissanen A, Andersen T, et al. Randomised placebo-controlled trial of orlistat for weight loss and prevention of weight regain in obese patients. European Multicentre Orlistat Study Group. Lancet. 1998;352(9123):167-72. [pmid: 9683204].
62 Vidgren H M, Agren J J, Valve R S, et al. The effect of orlistat on the fatty acid composition of serum lipid fractions in obese subjects. Clin Pharmacol Ther. 1999;66(3):315-22. [pmid: 10511068].
63 Rissanen P, Vahtera E, Krusius T, et al. Weight change and blood coagulability and fibrinolysis in healthy obese women. Int J Obes Relat Metab Disord. 2001;25(2):212-8. [pmid: 11410822].
64 Broom I. Randomised trial of the effect of orlistat on body weight and CVD risk profile in overweight and obese patients with co-morbidities. Int J Obes Relat Metab Disord. 2001;25 (Suppl):S106. [pmid: 11933881].
65 Broom I, Hughes E, Dodgson P, et al. on behalf of the Orlistat UK Study Group. The role of orlistat in the treatment of obese patients with mild to moderate hypercholesterolaemia: consequences for coronary risk. Br J Cariol 2002;9(8):460–8.
66 Muls E, Kolanowski J, Scheen A, et al. The effects of orlistat on weight and on serum lipids in obese patients with hypercholesterolemia: a randomized, double-blind, placebo-controlled, multicentre study. Int J Obes Relat Metab Disord. 2001;25(11):1713-21. [pmid: 11753595].
67 Deerochanawong Chaicharn. Effect of treatment with orlistat in overweight or obese Thai patients with type 2 diabetes. Diabetes. 2001;50 (Supplement 2):A433. [pmid: 11723075].
68 Shi Yi Fan, Zhu Jun Ren. Effect of orlistat on weight loss and glycemic control in overweight Chinese patients with type 2 diabetes. Diabetes. 2001;50 (Supplement 2):A101-A102. [pmid: 11723075].
69 Kelley D E, Bray G A, Pi-Sunyer F X, et al. Clinical efficacy of orlistat therapy in overweight and obese patientswith insulin-treated type 2 diabetes: a 1-year randomized controlledtrial. Diabetes Care. 2002;25(6):1033-1041. [pmid: 12032111].
70 Karhunen L, Franssila-Kallunki A, Rissanen P, et al. Effect of orlistat treatment on body composition and resting energy expenditure during a two-year weight-reduction programme in obese Finns. Int J Obes Relat Metab Disord. 2000;24(12):1567-72. [pmid: 11126207].
71 Krempf M, Louvet J P, Allanic H, et al. Weight reduction and long-term maintenance after 18 months treatment with orlistat for obesity. Int J Obes Relat Metab Disord. 2003;27(5):591-7. [pmid: 12704403].
72 Halpern A, Mancini M C, Suplicy H, et al. Latin-American trial of orlistat for weight loss and improvement in glycaemic profile in obese diabetic patients. Diabetes Obes Metab. 2003;5(3):180-8. [pmid: 12681025].
73 Lucas C P, Boldrin M N, Reaven G M. Effect of orlistat added to diet (30% of calories from fat) on plasma lipids, glucose, and insulin in obese patients with hypercholesterolemia. Am J Cardiol. 2003;91(8):961-4. [pmid: 12686336].
74 Bakris G, Calhoun D, Egan B, et al. Orlistat improves blood pressure control in obese subjects with treated but inadequately controlled hypertension. J Hypertens. 2002;20(11):2257-67. [pmid: 12409965].
75 Hanefeld M, Sachse G. The effects of orlistat on body weight and glycaemic control in overweight patients with type 2 diabetes: a randomized, placebo-controlled trial. Diabetes Obes Metab. 2002;4(6):415-23. [pmid: 12406041].
76 Miles J M, Leiter L, Hollander P, et al. Effect of orlistat in overweight and obese patients with type 2 diabetes treated with metformin. Diabetes Care. 2002;25(7):1123-8. [pmid: 12087008].
77 Rosenfalck A M, Hendel H, Rasmussen M H, et al. Minor long-term changes in weight have beneficial effects on insulin sensitivity and beta-cell function in obese subjects. Diabetes Obes Metab. 2002;4(1):19-28. [pmid: 11890163].
78 Naumov V G, Lupanov V P, Dotsenko Iu V, et al. [Six-month xenical (orlistat) therapy of patients with stable angina pectoris concomitant with obesity and hyperlipidemia]. Ter Arkh. 2002;74(1):47-51. [pmid: 11878059].
79 Gotfredsen A, Westergren Hendel H, Andersen T. Influence of orlistat on bone turnover and body composition. Int J Obes Relat Metab Disord. 2001;25(8):1154-60. [pmid: 11486790].
80 Reaven G, Segal K, Hauptman J, et al. Effect of orlistat-assisted weight loss in decreasing coronary heart disease risk in patients with syndrome X. Am J Cardiol. 2001;87(7):827-31. [pmid: 11274935].
81 Micic D, Ivkovic-Lazar T, Dragojevic R, et al. Orlistat, a gastrointestinal lipase inhibitor, in therapy of obesity with concomitant hyperlipidemia. Med Pregl. 1999;52(910):323-33. [pmid: 10624380].
82 Derosa G, Mugellini A, Ciccarelli L, et al. Randomized, double-blind, placebo-controlled comparison of the action of orlistat, fluvastatin, or both an anthropometric measurements, blood pressure, and lipid profile in obese patients with hypercholesterolemia prescribed a standardized diet. Clin Ther. 2003;25(4):1107-22. [pmid: 12809960].
83 Lindgarde F. The effect of orlistat on body weight and coronary heart disease risk profile in obese patients: the Swedish Multimorbidity Study. J Intern Med. 2000;248(3):245-54. [pmid: 10971792].
84 Broom I, Wilding J, Stott P, et al. Randomised trial of the effect of orlistat on body weight and cardiovascular disease risk profile in obese patients: UK Multimorbidity Study. Int J Clin Pract. 2002;56(7):494-9. [pmid: 12296610].
85 Haddock C K, Poston W S, Dill P L, et al. Pharmacotherapy for obesity: a quantitative analysis of four decades of published randomized clinical trials. Int J Obes Relat Metab Disord. 2002;26(2):262-73. [pmid: 11850760].
86 Kokkinos J, Levine S R. Possible association of ischemic stroke with phentermine. Stroke. 1993;24(2):310-3. [pmid: 8421834].
87 Kim I, Whitsett T L. Acute vasospasm associated with anorexiant use. J Okla State Med Assoc. 1988;81(7):395-8. [pmid: 3216246].
88 Breum L, Bjerre U, Bak J F, et al. Long-term effects of fluoxetine on glycemic control in obese patients with non-insulin-dependent diabetes mellitus or glucose intolerance: influence on muscle glycogen synthase and insulin receptor kinase activity. Metabolism. 1995;44(12):1570-6. [pmid: 8786726].
89 Goldstein D J, Rampey A H Jr, Enas G G, et al. Fluoxetine: a randomized clinical trial in the treatment of obesity. Int J Obes Relat Metab Disord. 1994;18(3):129-35. [pmid: 8186809].
90 Marcus M D, Wing R R, Ewing L, et al. A double-blind, placebo-controlled trial of fluoxetine plus behavior modification in the treatment of obese binge-eaters and non-binge- eaters. Am J Psychiatry. 1990;147(7):876-81. [pmid: 2192563].
91 Darga L L, Carroll-Michals L, Botsford S J, et al. Fluoxetine's effect on weight loss in obese subjects. Am J Clin Nutr. 1991;54(2):321-5. [pmid: 1858696].
92 O'Kane M, Wiles P G, Wales J K. Fluoxetine in the treatment of obese type 2 diabetic patients. Diabet Med. 1994;11(1):105-10. [pmid: 8181239].
93 Connolly V M, Gallagher A, Kesson C M. A study of fluoxetine in obese elderly patients with type 2 diabetes. Diabet Med. 1995;12(5):416-8. [pmid: 7648804].
94 Mendoza Espejo R, Diaz Perez de Madrid J, Buitrago F. [Effectiveness of serotonergic agonists in the treatment of obese patients]. Aten Primaria. 1995;16(6):364-6. [pmid: 7488690].
95 Gray D S, Fujioka K, Devine W, et al. Fluoxetine treatment of the obese diabetic. Int J Obes Relat Metab Disord. 1992;16(3):193-8. [pmid: 1317828].
96 Wadden T A, Bartlett S J, Foster G D, et al. Sertraline and relapse prevention training following treatment by very- low-calorie diet: a controlled clinical trial. Obes Res. 1995;3(6):549-57. [pmid: 8653531].
97 Anderson James W, Greenway Frank, Fujioka Ken, et al. Buproprion SR significantly enhances weight loss when used with a moderate-intensity lifestyle intervention. Diabetes. 2001;50 (Supplement 2):A21. [pmid: 11723075].
98 Croft H, Houser T L, Jamerson B D, et al. Effect on body weight of bupropion sustained-release in patients with major depression treated for 52 weeks. Clin Ther. 2002;24(4):662-72. [pmid: 12017410].
99 Jain A K, Kaplan R A, Gadde K M, et al. Bupropion SR vs. placebo for weight loss in obese patients with depressive symptoms. Obes Res. 2002;10(10):1049-56. [pmid: 12376586].
100 Gilliam F G, Veloso F, Bomhof M A, et al. A dose-comparison trial of topiramate as monotherapy in recently diagnosed partial epilepsy. Neurology. 2003;60(2):196-202. [pmid: 12552030].
101 Bray G, Klein S, Levy B, Fitchet M, Perry B. Topiramate produces dose-related weight loss in obese patients. Presented at the 62nd American Diabetes Association Scientific Sessions. 2002 (Abstract)
102 Stenlof K, Rossner S, Vercruysse F, Perry B, Fitchet M, Sjostrom L. Safety and efficacy of Topiramate in the treatment of Type II diabetic obese subjects: A randomized, double-blind, placebo-controlled trial. Presented at the 18th International Diabetes Federation Congress. 2003 (Abstract)
103 Stenlof K, Rossner S, Vercruysse F, Perry B, Fitchet M, Sjostrom L. Topiramate decreases weight and blood pressure in obese subjects with Type II diabetes. Presented at the North American Association of rthe Study of Obesity 2003 Annual Scientific Meeting. 2003 (Abstract)
104 Rissanen A, Wilding J, Van Gaal L, Vercruysse F, Perry B, Fitchet M. The effect of Topiramate on body weight and blood pressure in obese subjects: A long-term, randomized, placebo-controlled trial. Presented at the 18th Internation Diabetes Federation Congress. 2003 (Abstract)
105 Pud'homme D, Firchet M, Almeras N, Dumont M, Tremblay A, Despres JP. Six-month Topiramate treatment reduces body weight and blood pressure. Presented at the North American Association for the Study of Obesity 2003 Annual Scientific Meeting. 2003 (Abstract)
106 Tonstad S, Levy B, Perry B, Fitchet M. Topiramate decreases weight and lowers blood pressure in obese subjects with hypertension. Presented at the North American Association for the Study of Obesity 2003 Annual Scientific Meeting. 2003 (Abstract)
107 Caterson I, Astrup A, Zelissen P, Guy-Grand B, Carruba M, Levy B, et al. The long-term effect of Topiramate on body weight maintenance after low-calorie diet-induced wieght loss in obese subjects. Presented at the 18th International Diabetes Federation Congress. 2003 (Abstract)
108 Gadde K M, Franciscy D M, Wagner H R 2nd, et al. Zonisamide for weight loss in obese adults: a randomized controlled trial. JAMA. 2003;289(14):1820-5. [pmid: 12684361].
109 Sjostrom C D, Peltonen M, Sjostrom L. Blood pressure and pulse pressure during long-term weight loss in the obese: the Swedish Obese Subjects (SOS) Intervention Study. Obes Res. 2001;9(3):188-95. [pmid: 11323444].
110 Sjostrom C D, Peltonen M, Wedel H, et al. Differentiated long-term effects of intentional weight loss on diabetes and hypertension. Hypertension. 2000;36(1):20-5. [pmid: 10904007].
111 Karason K, Lindroos A K, Stenlof K, et al. Relief of cardiorespiratory symptoms and increased physical activity after surgically induced weight loss: results from the Swedish Obese Subjects study. Arch Intern Med. 2000;160(12):1797-802. [pmid: 10871973].
112 Karason K, Molgaard H, Wikstrand J, et al. Heart rate variability in obesity and the effect of weight loss. Am J Cardiol. 1999;83(8):1242-7. [pmid: 10215292].
113 Karason K, Wikstrand J, Sjostrom L, et al. Weight loss and progression of early atherosclerosis in the carotid artery: a four-year controlled study of obese subjects. Int J Obes Relat Metab Disord. 1999;23(9):948-56. [pmid: 10490801].
114 Karlsson J, Sjostrom L, Sullivan M. Swedish obese subjects (SOS)-an intervention study of obesity. Two-year follow-up of health-related quality of life (HRQL) and eating behavior after gastric surgery for severe obesity. Int J Obes Relat Metab Disord. 1998;22(2):113-26. [pmid: 9504319].
115 Narbro K, Agren G, Jonsson E, et al. Sick leave and disability pension before and after treatment for obesity: a report from the Swedish Obese Subjects (SOS) study. Int J Obes Relat Metab Disord. 1999;23(6):619-24. [pmid: 10411235].
116 Sjostrom C D, Lissner L, Wedel H, et al. Reduction in incidence of diabetes, hypertension and lipid disturbances after intentional weight loss induced by bariatric surgery: the SOS Intervention Study. Obes Res. 1999;7(5):477-84. [pmid: 10509605].
117 Weiner R, Bockhorn H, Rosenthal R, et al. A prospective randomized trial of different laparoscopic gastric banding techniques for morbid obesity. Surgical endoscopy. 2001;15(1):63-8. [pmid: 11178766].
118 de Wit L T, Mathus-Vliegen L, Hey C, et al. Open versus laparoscopic adjustable silicone gastric banding: a prospective randomized trial for treatment of morbid obesity. Annals of surgery. 1999;230(6):800-5. [pmid: 10615935]. [pmcid: 1420944].
119 Brolin R E, Kenler H, Gorman J, et al. Long-limb gastric bypass in the superobese. A prospective randomized study. Annals of surgery. 1992;215(4):387-95. [pmid: 1558421]. [pmcid: 1242457].
120 Andersen T, Backer O G, Stokholm K H, et al. Randomized trial of diet and gastroplasty compared with diet alone in morbid obesity. New England journal of medicine. 1984;310(6):352-6. [pmid: 6690963].
121 Andersen T, Backer O G, Stokholm K, et al. [Gastroplasty versus very low calorie diet in morbid obesity. Short-term results of a randomized clinical trial]: <Original> Gastroplastik versus ekstrem lavkalorie-diaet (very-low-calorie diet) ved svaer adipositas. Korttidsresultater af en randomiseret klinisk undersogelse. Ugeskrift for laeger. 1982;144(6):390-4. [pmid: 7041386].
122 Lechner G W, Callender A K. Subtotal gastric exclusion and gastric partitioning: a randomized prospective comparison of one hundred patients. Surgery. 1981;90(4):637-44. [pmid: 7025315].
123 Quaade F. Jejunoileal bypass for morbid obesity. A bibliographic study and a randomized clinical trial. Surgical clinics of North America. 1979;59(6):1055-69. [pmid: 394374].
124 The Danish Obesity Project. Randomised trial of jejunoileal bypass versus medical treatment in morbid obesity. Lancet 1979;2(8155):1255–8.
125 Laws H L, Piantadosi S. Superior gastric reduction procedure for morbid obesity: a prospective, randomized trial. Ann Surg. 1981;193(3):334-40. [pmid: 7212793]. [pmcid: 1345071].
126 Viddal K O. Intestinal bypass. A randomized, prospective clinical study of end-to-side and end-to-end jejunoileal bypass. Scand J Gastroenterol. 1983;18(5):627-34. [pmid: 6675183].
127 Naslund I, Wickbom G, Christoffersson E, et al. A prospective randomized comparison of gastric bypass and gastroplasty. Complications and early results. Acta Chir Scand. 1986;152:681-9. [pmid: 3551425].
128 Sugerman H J, Starkey J V, Birkenhauer R. A randomized prospective trial of gastric bypass versus vertical banded gastroplasty for morbid obesity and their effects on sweets versus non- sweets eaters. Ann Surg. 1987;205(6):613-24. [pmid: 3296971]. [pmcid: 1493086].
129 Hall J C, Watts J M, O'Brien P E, et al. Gastric surgery for morbid obesity. The Adelaide Study. Ann Surg. 1990;211(4):419-27. [pmid: 2181950]. [pmcid: 1358027].
130 MacLean LD, Rhode BM, Sampalis J, et al. Results of the surgical treatment of obesity. Am J Surg 1993;165(1):155–60; discussion 160–2.
131 Howard L, Malone M, Michalek A, et al. Gastric Bypass and Vertical Banded Gastroplasty- a Prospective Randomized Comparison and 5-Year Follow-up. Obes Surg. 1995;5(1):55-60. [pmid: 10733794].
132 Buckwalter J A. A prospective comparison of the jejunoileal and gastric bypass operations for morbid obesity. World J Surg. 1977;1(6):757-68. [pmid: 607594].
133 Griffen W O Jr, Young V L, Stevenson C C. A prospective comparison of gastric and jejunoileal bypass procedures for morbid obesity. Ann Surg. 1977;186(4):500-9. [pmid: 907395]. [pmcid: 1396298].
134 Andersen T, Stokholm K H, Backer O G, et al. Long-term (5-year) results after either horizontal gastroplasty or very- low-calorie diet for morbid obesity. Int J Obes. 1988;12(4):277-84. [pmid: 3058614].
135 Andersen T, Backer O G, Astrup A, et al. Horizontal or vertical banded gastroplasty after pretreatment with very- low-calorie formula diet: a randomized trial. Int J Obes. 1987;11(3):295-304. [pmid: 3312050].
136 Lundell L, Ruth M, Olbe L. Vertical banded gastroplasty or gastric banding for morbid obesity: effects on gastro-oesophageal reflux. Eur J Surg. 1997;163(7):525-31. [pmid: 9248987].
137 Nguyen NT, Goldman C, Rosenquist CJ, et al. Laparoscopic versus open gastric bypass: a randomized study of outcomes, quality of life, and costs. Ann Surg 2001;234(3):279–89; discussion 289–91.
138 Choban P S, Flancbaum L. The effect of Roux limb lengths on outcome after Roux-en-Y gastric bypass: a prospective, randomized clinical trial. Obes Surg. 2002;12(4):540-5. [pmid: 12194548].
139 Westling A, Gustavsson S. Laparoscopic vs open Roux-en-Y gastric bypass: a prospective, randomized trial. Obes Surg. 2001;11(3):284-92. [pmid: 11433902].
140 Agren G, Naslund I. A prospective randomized comparison of vertical banded gastroplasty (VBG), loop gastric bypass (GBY), and gastric banding (GB). Int J Obes. 1989;13:595.
141 Van Rij A M. Gastric bypass and gastric partitioning in morbid obesity: results of a controlled trial. Aus NZ J Med. 1984;14 (3 suppl 1):340.
142 VanWoert J, Michalek A, Alger S, et al. A prospective randomized trial (PRT) of gastric bypass (GB) versus vertical banded gatroplasty (VBG) for morbid obesity (MO). Clinical Research. 1992;40(2):A642.
143 Naslund I. The size of the gastric outlet and the outcome of surgery for obesity. Acta Chir Scand. 1986;152:205-10. [pmid: 3716740].
144 Naslund I, Beckman K W. Gastric emptying rate after gastric bypass and gastroplasty. Scand J Gastroenterol. 1987;22(2):193-201. [pmid: 3554493].
145 Naslund I. Gastric bypass versus gastroplasty. A prospective study of differences in two surgical procedures for morbid obesity. Acta Chir Scand Suppl. 1987;536:1-60. [pmid: 3475886].
146 Naslund I, Hallgren P, Sjostrom L. Fat cell weight and number before and after gastric surgery for morbid obesity in women. Int J Obes. 1988;12(3):191-7. [pmid: 3391735].
147 Naslund I, Jarnmark I, Andersson H. Dietary intake before and after gastric bypass and gastroplasty for morbid obesity in women. Int J Obes. 1988;12(6):503-13. [pmid: 3069767].
148 Nilsell K, Thorne A, Sjostedt S, et al. Prospective randomised comparison of adjustable gastric banding and vertical banded gastroplasty for morbid obesity. Eur J Surg. 2001;167(7):504-9. [pmid: 11560385].
149 Hesse U J, Berrevoet F, Ceelen W, et al. [Adjustable silicone gastric banding (ASGB, Bioenterics) and the Swedish adjustable gastric banding (SAGB, Obtech) in treatment of morbid obesity]: <Original> Das anpassbare Silicon Gastric Banding (ASGB, Bioenterics) und das Schwedische anpassbare Gastric Banding (SAGB, Obtech) zur Behandlung der morbiden Obesitas. Der Chirurg; Zeitschrift fur alle Gebiete der operativen Medizen. 2001;72(1):14-8. [pmid: 11225451].
150 Brolin R E, Bradley L J, Wilson A C, et al. Lipid risk profile and weight stability after gastric restrictive operations for morbid obesity. J Gastrointest Surg. 2000;4(5):464-9. [pmid: 11077320].
151 van Gemert W G, Adang E M, Greve J W, et al. Quality of life assessment of morbidly obese patients: effect of weight- reducing surgery. Am J Clin Nutr. 1998;67(2):197-201. [pmid: 9459366].
152 Karason K, Wallentin I, Larsson B, et al. Effects of obesity and weight loss on left ventricular mass and relative wall thickness: survey and intervention study. BMJ. 1997;315(7113):912-6. [pmid: 9361540]. [pmcid: 2127625].
153 Mason E E, Doherty C, Cullen J J, et al. Vertical gastroplasty: evolution of vertical banded gastroplasty. World J Surg. 1998;22(9):919-24. [pmid: 9717417].
154 MacLean L, Rhode B. Does Genetic Predisposition Influence Surgical Results of Operations for Obesity?. Obes Surg. 1996;6(2):132-137. [pmid: 10729853].
155 Matthews B D, Sing R F, DeLegge M H, et al. Initial results with a stapled gastrojejunostomy for the laparoscopic isolated Roux-en-Y gastric bypass. Am J Surg. 2000;179(6):476-81. [pmid: 11004334].
156 O'Brien P E, Brown W A, Smith A, et al. Prospective study of a laparoscopically placed, adjustable gastric band in the treatment of morbid obesity. Br J Surg. 1999;86(1):113-8. [pmid: 10027373].
157 Peace K, Dyne J, Russell G, et al. Psychobiological effects of gastric restriction surgery for morbid obesity. N Z Med J. 1989;102(862):76-8. [pmid: 2919020].
158 Toppino M, Morino M, Bonnet G, et al. Laparoscopic surgery for morbid obesity: preliminary results from SICE registry (Italian Society of Endoscopic and Minimally Invasive Surgery). Obes Surg. 1999;9(1):62-5. [pmid: 10065587].
159 Toppino M, Morino M, Capuzzi P, et al. Outcome of vertical banded gastroplasty. Obes Surg. 1999;9(1):51-4. [pmid: 10065583].
160 Yale C E, Weiler S J. Weight control after vertical banded gastroplasty for morbid obesity. Am J Surg. 1991;162(1):13-8. [pmid: 2063963].
161 Aghahosseini H, Roulet D, Cavin R. [Treatment of morbid obesity with adjustable gastric prosthesis: experience and results at the Riviera Hospital in Montreux]. Rev Med Suisse Romande. 2001;121(10):709-12. [pmid: 11715285].
162 Kalfarentzos F, Dimakopoulos A, Kehagias I, et al. Vertical banded gastroplasty versus standard or distal Roux-en-Y gastric bypass based on specific selection criteria in the morbidly obese: preliminary results. Obes Surg. 1999;9(5):433-42. [pmid: 10605899].
163 van de Weijgert E J, Ruseler C H, Elte J W. Long-term follow-up after gastric surgery for morbid obesity: preoperative weight loss improves the long-term control of morbid obesity after vertical banded gastroplasty. Obes Surg. 1999;9(5):426-32. [pmid: 10605898].
164 Dargent J. Laparoscopic adjustable gastric banding: lessons from the first 500 patients in a single institution. Obes Surg. 1999;9(5):446-52. [pmid: 10605901].
165 Miller K, Hell E. Laparoscopic adjustable gastric banding: a prospective 4-year follow-up study. Obes Surg. 1999;9(2):183-7. [pmid: 10340775].
166 Alden J F. Gastric and jejunoileal bypass. A comparison in the treatment of morbid obesity. Arch Surg. 1977;112(7):799-806. [pmid: 880023].
167 Letiexhe M R, Scheen A J, Gerard P L, et al. Post-gastroplasty recovery of ideal body weight normalizes glucose and insulin metabolism in obese women. J Clin Endocrinol Metab. 1995;80:334-369. [pmid: 7852491].
168 Melissas J, Christodoulakis M, Spyridakis M, et al. Disorders associated with clinically severe obesity: significant improvement after surgical weight reduction. South Med J. 1998;91(12):1143-8. [pmid: 9853727].
169 Bloomston M, Zervos E E, Camps M A, et al. Outcome following bariatric surgery in super versus morbidly obese patients: does weight matter?. Obes Surg. 1997;7(5):414-9. [pmid: 9730495].
170 Balsiger B M, Poggio J L, Mai J, et al. Ten and more years after vertical banded gastroplasty as primary operation for morbid obesity. J Gastrointest Surg. 2000;4(6):598-605. [pmid: 11307094].
171 Davila-Cervantes A, Ganci-Cerrud G, Gamino R, et al. Open vs. laparoscopic vertical banded gastroplasty: a case control study with a 1-year follow-up. Obes Surg. 2000;10(5):409-12. [pmid: 11054244].
172 Alper D, Ramadan E, Vishne T, et al. Silastic ring vertical gastroplasty- long-term results and complications. Obes Surg. 2000;10(3):250-4. [pmid: 10929157].
173 Choi Y, Frizzi J, Foley A, et al. Patient satisfaction and results of vertical banded gastroplasty and gastric bypass. Obes Surg. 1999;9(1):33-5. [pmid: 10065578].
174 Baltasar A, Bou R, Arlandis F, et al. Vertical banded gastroplasty at more than 5 years. Obes Surg. 1998;8(1):29-34. [pmid: 9562483].
175 Stoner J, Stoner P, Sytsma J. 42-month preliminary follow-up of the silastic ring vertical banded gastroplasty. Obes Surg. 1997;7(6):513-5. [pmid: 9730510].
176 Yashkov YI, Timoshin AD, Oppel TA. Vertical banded gastroplasty: first experience in Russia. Obes Surg 1997;7(4):317–20; discussion 321.
177 Goulding S T, Hovell B C. Anaesthetic experience of vertical banded gastroplasty. Br J Anaesth. 1995;75(3):301-6. [pmid: 7547048].
178 Schauer P R, Ikramuddin S, Gourash W, et al. Outcomes after laparoscopic Roux-en-Y gastric bypass for morbid obesity. Ann Surg. 2000;232(4):515-29. [pmid: 10998650]. [pmcid: 1421184].
179 Nguyen NT, Ho HS, Palmer LS, et al. A comparison study of laparoscopic versus open gastric bypass for morbid obesity. J Am Coll Surg 2000;191(2):149–55; discussion 155–7.
180 Choban P S, Onyejekwe J, Burge J C, et al. A health status assessment of the impact of weight loss following Roux- en-Y gastric bypass for clinically severe obesity. J Am Coll Surg. 1999;188(5):491-7. [pmid: 10235576].
181 Doldi S B, Micheletto G, Lattuada E, et al. Adjustable gastric banding: 5-year experience. Obes Surg. 2000;10(2):171-3. [pmid: 10782180].
182 Freeman J B, Kotlarewsky M, Phoenix C. Weight loss after extended gastric bypass. Obes Surg. 1997;7(4):337-44. [pmid: 9730521].
183 Crampton N A, Izvornikov V, Stubbs R S. Silastic ring gastric bypass: results in 64 patients. Obes Surg. 1997;7(6):489-94. [pmid: 9730506].
184 Oh CH, Kim HJ, Oh S. Weight loss following transected gastric bypass with proximal Roux-en-Y. Obes Surg 1997;7(2):142–7; discussion 148.
185 Nowara H A. Egyptian experience in laparoscopic adjustable gastric banding (technique, complications and intermediate results). Obes Surg. 2001;11(1):70-5. [pmid: 11361172].
186 Wiesner W, Schob O, Hauser R S, et al. Adjustable laparoscopic gastric banding in patients with morbid obesity: radiographic management, results, and postoperative complications. Radiology. 2000;216(2):389-94. [pmid: 10924559].
187 De Luca M, de Werra C, Formato A, et al. Laparotomic vs laparoscopic lap-band: 4-year results with early and intermediate complications. Obes Surg. 2000;10(3):266-8. [pmid: 10929160].
188 Suter M, Bettschart V, Giusti V, et al. A 3-year experience with laparoscopic gastric banding for obesity. Surg Endosc. 2000;14(6):532-6. [pmid: 10890959].
189 Suter M, Giusti V, Heraief E, et al. Early results of laparoscopic gastric banding compared with open vertical banded gastroplasty. Obes Surg. 1999;9(4):374-80. [pmid: 10484296].
190 Abu-Abeid S, Szold A. Results and complications of laparoscopic adjustable gastric banding: an early and intermediate experience. Obes Surg. 1999;9(2):188-90. [pmid: 10340776].
191 Forsell P, Hallerback B, Glise H, et al. Complications following Swedish adjustable gastric banding: a long-term follow-up. Obes Surg. 1999;9(1):11-6. [pmid: 10065574].
192 Doherty C, Maher J W, Heitshusen D S. Prospective investigation of complications, reoperations, and sustained weight loss with an adjustable gastric banding device for treatment of morbid obesity. J Gastrointest Surg. 1998;2(1):102-8. [pmid: 9841975].
193 Forestieri P, Meucci L, De Luca M, et al. Two years of practice in adjustable silicone gastric banding (LAP- BAND): evaluation of variations of body mass index, percentage ideal body weight and percentage excess body weight. Obes Surg. 1998;8(1):49-52. [pmid: 9562487].
194 Forsell P, Hellers G. The Swedish Adjustable Gastric Banding (SAGB) for morbid obesity: 9 year experience and a 4-year follow-up of patients operated with a new adjustable band. Obes Surg. 1997;7(4):345-51. [pmid: 9730522].
195 Horchner R, Tuinebreijer W. Improvement of physical functioning of morbidly obese patients who have undergone a Lap-Band operation: one-year study. Obes Surg. 1999;9(4):399-402. [pmid: 10484301].
196 Randolph J G, Weintraub W H, Rigg A. Jejunoileal bypass for morbid obesity in adolescents. J Pediatr Surg. 1974;9(3):341-5. [pmid: 4843988].
197 Rigg CA. Proceedings: Jejunoileal bypass in morbidly obese adolescent. Acta Paediatr Scand Suppl 1975;(256):62–4.
198 White J J, Cheek D, Haller J A Jr. Small bowel bypass is applicable for adolescents with morbid obesity. Am Surg. 1974;40(12):704-8. [pmid: 4429281].
199 Pories W J, Flickinger E G, Meelheim D, et al. The effectiveness of gastric bypass over gastric partition in morbid obesity: consequence of distal gastric and duodenal exclusion. Ann Surg. 1982;196(4):389-99. [pmid: 7125726]. [pmcid: 1352695].
200 Hess D S, Hess D W. Biliopancreatic diversion with a duodenal switch. Obes Surg. 1998;8(3):267-82. [pmid: 9678194].
201 Marceau P, Biron S, Bourque R A, et al. Biliopancreatic Diversion with a New Type of Gastrectomy. Obes Surg. 1993;3(1):29-35. [pmid: 10757900].
202 Mason E E. Vertical banded gastroplasty for obesity. Arch Surg. 1982;117(5):701-6. [pmid: 7073493].
203 Wittgrove A C, Clark G W. Laparoscopic gastric bypass, Roux-en-Y- 500 patients: technique and results, with 3–60 month follow-up. Obes Surg. 2000;10(3):233-9. [pmid: 10929154].
204 Higa K D, Boone K B, Ho T. Complications of the laparoscopic Roux-en-Y gastric bypass: 1,040 patients-what have we learned?. Obes Surg. 2000;10(6):509-13. [pmid: 11175957].
205 Higa KD, Boone KB, Ho T, et al. Laparoscopic Roux-en-Y gastric bypass for morbid obesity: technique and preliminary results of our first 400 patients. Arch Surg 2000;135(9):1029–33; discussion 1033–4.
206 Scopinaro N, Gianetta E, Adami G F, et al. Biliopancreatic diversion for obesity at eighteen years. Surgery. 1996;119(3):261-8. [pmid: 8619180].
207 Belachew M, Legrand M, Vincent V, et al. Laparoscopic adjustable gastric banding. World J Surg. 1998;22(9):955-63. [pmid: 9717421].
208 Das S K, Roberts S B, Kehayias J J, et al. Body composition assessment in extreme obesity and after massive weight loss induced by gastric bypass surgery. Am J Physiol Endocrinol Metab. 2003;284(6):E1080-8. [pmid: 12604503].
209 Tacchino R M, Mancini A, Perrelli M, et al. Body composition and energy expenditure: relationship and changes in obese subjects before and after biliopancreatic diversion. Metabolism. 2003;52(5):552-8. [pmid: 12759883].
210 Al-Jiffry B O, Shaffer E A, Saccone G T, et al. Changes in gallbladder motility and gallstone formation following laparoscopic gastric banding for morbid obesity. Can J Gastroenterol. 2003;17(3):169-74. [pmid: 12677265].
211 Weiner R, Blanco-Engert R, Weiner S, et al. Outcome after laparoscopic adjustable gastric banding - 8 years experience. Obes Surg. 2003;13(3):427-34. [pmid: 12841906].
212 Olbers T, Lonroth H, Fagevik-Olsen M, et al. Laparoscopic gastric bypass: development of technique, respiratory function, and long-term outcome. Obes Surg. 2003;13(3):364-70. [pmid: 12841895].
213 Mittermair R P, Weiss H, Nehoda H, et al. Laparoscopic Swedish adjustable gastric banding: 6-year follow-up and comparison to other laparoscopic bariatric procedures. Obes Surg. 2003;13(3):412-7. [pmid: 12841903].
214 Courcoulas A, Perry Y, Buenaventura P, et al. Comparing the outcomes after laparoscopic versus open gastric bypass: a matched paired analysis. Obes Surg. 2003;13(3):341-6. [pmid: 12841890].
215 Perugini RA, Mason R, Czerniach DR, et al. Predictors of complication and suboptimal weight loss after laparoscopic Roux-en-Y gastric bypass: a series of 188 patients. Arch Surg 2003;138(5):541–5; discussion 545–6.
216 Suter M, Giusti V, Heraief E, et al. Laparoscopic Roux-en-Y gastric bypass: initial 2-year experience. Surg Endosc. 2003;17(4):603-9. [pmid: 12582767].
217 de Zwaan M, Lancaster K L, Mitchell J E, et al. Health-related quality of life in morbidly obese patients: effect of gastric bypass surgery. Obes Surg. 2002;12(6):773-80. [pmid: 12568181].
218 Reddy RM, Riker A, Marra D, et al. Open Roux-en-Y gastric bypass for the morbidly obese in the era of laparoscopy. Am J Surg 2002;184(6):611–5; discussion 615–6.
219 Dymek M P, Le Grange D, Neven K, et al. Quality of life after gastric bypass surgery: a cross-sectional study. Obes Res. 2002;10(11):1135-42. [pmid: 12429877].
220 Papasavas P K, Hayetian F D, Caushaj P F, et al. Outcome analysis of laparoscopic Roux-en-Y gastric bypass for morbid obesity. The first 116 cases. Surg Endosc. 2002;16(12):1653-7. [pmid: 12239643].
221 Hedenbro J L, Frederiksen S G. Fully stapled gastric bypass with isolated pouch and terminal anastomosis: 1–3 year results. Obes Surg. 2002;12(4):546-50. [pmid: 12194549].
222 Pontiroli A E, Pizzocri P, Librenti M C, et al. Laparoscopic adjustable gastric banding for the treatment of morbid (grade 3) obesity and its metabolic complications: a three-year study. J Clin Endocrinol Metab. 2002;87(8):3555-61. [pmid: 12161474].
223 Feng J J, Gagner M. Laparoscopic biliopancreatic diversion with duodenal switch. Semin Laparosc Surg. 2002;9(2):125-9. [pmid: 12152155].
224 Gustavsson S, Westling A. Laparoscopic adjustable gastric banding: complications and side effects responsible for the poor long-term outcome. Semin Laparosc Surg. 2002;9(2):115-24. [pmid: 12152154].
225 Lujan J A, Hernandez Q, Frutos M D, et al. Laparoscopic gastric bypass in the treatment of morbid obesity. Preliminary results of a new technique. Surg Endosc. 2002;16(12):1658-62. [pmid: 12140634].
226 Torgerson J S, Sjostrom L. The Swedish Obese Subjects (SOS) study--rationale and results. Int J Obes Relat Metab Disord. 2001;25 Suppl 1:S2-4. [pmid: 11466577].
227 Alpert M A, Terry B E, Kelly D L. Effect of weight loss on cardiac chamber size, wall thickness and left ventricular function in morbid obesity. Am J Cardiol. 1985;55(6):783-6. [pmid: 3976525].
228 Alpert M A, Lambert C R, Panayiotou H, et al. Relation of duration of morbid obesity to left ventricular mass, systolic function, and diastolic filling, and effect of weight loss. Am J Cardiol. 1995;76(16):1194-7. [pmid: 7484912].
229 Sugerman HJ, Baron PL, Fairman RP, Evans CR, Vetrovec GW. Hemodynamic dysfunction in obesity hypoventilation syndrome and the effects of treatment with surgically induced weight loss. Ann Surg. 1988 207:604–13.(Abstract)
230 Karason K, Wallentin I, Larsson B, Sjostrom L. Effects of obesity and weight loss on cardiac function and valvular performance. Obes Res. 1998 6:422–429.(Abstract)
231 Kanoupakis E, Michaloudis D, Fraidakis O, Parthenakis F, Vardas P, Melissas J. Left ventricular function and cardiopulmonary performance following surgical treatment of morbid obesity. Obes Surg. 2001 11:552–558.(Abstract)
232 Smith SC, Edwards CB, Goodman GN. Symptomatic and clinical improvement in morbidly obese patients with gastroesophageal reflux disease following Roux-en-Y gastric bypass. Obes Surg. 1997 7:479–484.(Abstract)
233 Frezza EE, Ikramuddin S, Gourash W, Rakitt T, Kingston A, Luketich J, et al. Symptomatic improvement in gastroesophageal reflux disease (GERD) following laparoscopic Roux-en-Y gastric bypass. Surg Endosc. 2002 16:1027–1031.(Abstract)
234 Macgregor A, Greenberg RA. Effect of surgically induced weight loss on asthma in the morbidly obese. Obes Surg. 1993 3:15–21.(Abstract)
235 Dixon JB, Chapman L, O'Brien P. Marked improvement in asthma after Lap-Band® surgery for morbid obesity. Obes Surg. 1999 9:385–389.(Abstract)
236 Deitel M, Khanna RK, Hagen J, Ilves R. Vertical banded gastroplasty as an antireflux procedure. Am J Surg. 1988 155:512–4.(Abstract)
237 Naslund E, Granstrom L, Melcher A, Stockeld D, Backman L. Gastro-oesophageal reflux before and after vertical banded gastroplasty in the treatment of obesity. Eur J Surg. 1996 162:303–6.(Abstract)
238 Kim C H, Sarr M G. Severe reflux esophagitis after vertical banded gastroplasty for treatment of morbid obesity. Mayo Clin Proc. 1992;67(1):33-5. [pmid: 1732688].
239 Sugerman H J, Kellum J M Jr, DeMaria E J, et al. Conversion of failed or complicated vertical banded gastroplasty to gastric bypass in morbid obesity. Am J Surg. 1996;171(2):263-9. [pmid: 8619465].
240 Sugerman HJ, Felton WL, Sismanis A, Salvant JB, Kellum JM. Effects of surgically induced weight loss on pseudotumor cerebri in morbid obesity. Neurology. 1995 45:1655–9.(Abstract)
241 Sugerman HJ, Felton WL 3^rd^, Sismanis A, et al. Gastric surgery for pseudotumor cerebri associated with severe obesity. Ann Surg. 1999 21:682–5.(Abstract)
242 Deitel M, Toan BT, Stone EM, et al. Sex hormone changes accompanying loss of massive excess weight. Gastroenterol Clin N Amer. 1987 16:511–5.(Abstract)
243 Richards D S, Miller D K, Goodman G N. Pregnancy after gastric bypass for morbid obesity. J Reprod Med. 1987;32(3):172-6. [pmid: 3572896].
244 Marceau P, Biron S, Hould FS, Lebel S, Marceau S, Simard S, et al. Outcome of pregnancies after obesity surgery. In: Guy-Grand B, Ailhaud G. (Eds) Progress in Obesity Research:8. London: John Libbey and Company; 1999. p. 795–802.
245 Dixon J B, Dixon M E, O'Brien P E. Pregnancy after Lap-Band surgery: management of the band to achieve healthy weight outcomes. Obes Surg. 2001;11(1):59-65. [pmid: 11361170].
246 Friedman D, Cunco S, Valenzano M, Marinari GM, Adami GF, Gianetti E, et al. Pregnancies in an 18-year follow-up after biliopancreatic diversion. Obes Surg. 1995 5:308–313.(Abstract)
247 Wittgrove AC, Jester L, Wittgrove P, Clark GW. Pregnancy following gastric bypass for morbid obesity. Obes Surg. 1998 8:461–464.(Abstract)
248 Bump RC, Sugerman HJ, Fantl JA, et al. Obesity and lower urinary tract function in women: effects of surgically induced weight loss. Am J Obstet Gynecol. 1992 167:392–7.(Abstract)
249 Parvizi J, Trousadale RT, Sarr MG. Total joint arthroplasty in patients surgically treated for morbid obesity. J Arthroplasty. 2000 15:(8)1003–1008.(Abstract)
250 Peltonen M, Lindroos AK, Torgerson JS. Musculoskeletal pain in the obese: a comparison with the general population and long-term changes after conventional and surgical obesity treatment. Pain. 2003 104:549–557.(Abstract)
251 Melissas J, Volakakis E, Hadjipavlou A. Low-back pain in morbidly obese patients and the effect of weight loss following surgery. Obes Surg. 2003 13:389–393.(Abstract)
252 Zacchi P, Mearin F, Humbert P, et al. Effect of obesity on gastroesophageal resistance to flow in man. Dig Dis Sci . 1991 36:1473–80.(Abstract)
253 Ranlov I, Hardt F. Regression of liver steatosis following gastroplasty or gastric bypass for morbid obesity. Degestion. 1990 47:208–214.(Abstract)
254 Sugerman H J, Sugerman E L, Wolfe L, et al. Risks and benefits of gastric bypass in morbidly obese patients with severe venous stasis disease. Ann Surg. 2001;234(1):41-6. [pmid: 11460821]. [pmcid: 1421946].
255 Silverman EM, Sapala JA, Appelman HD. Regression of hepatic steatosis in morbidly obese persons after gastric bypass. Am J Clin Pathol . 1995 104:23–31.(Abstract)
256 Luyckx FH, Desaive C, Thiry A, Dewe W, Scheen AJ, Gielen JE, et al. Liver abnormalities in severely obese subjects: effect of drastic weight loss after gastroplasty. Int J Obes Relat Metab Disord . 1998 22:222–226.(Abstract)
257 Kral JG, Thung SN, Biron S, Hould FS, et al. Effects of surgical treatment of the metabolic syndrome on liver fibrosis and cirrhosis. Surgery. 2004 135:48–58.(Abstract)
258 Rand C S, Macgregor A, Hankins G. Gastric bypass surgery for obesity: weight loss, psychosocial outcome, and morbidity one and three years later. South Med J. 1986;79(12):1511-4. [pmid: 3787289].
259 Kral J G, Sjostrom L V, Sullivan M B. Assessment of quality of life before and after surgery for severe obesity. Am J Clin Nutr. 1992;55 (2 Suppl):611S-614S. [pmid: 1442668].
260 Dixon J B, O'Brien P E. Changes in comorbidities and improvements in quality of life after LAP-BAND placement. Am J Surg. 2002;184(6B):51S-54S. [pmid: 12527352].
261 Ballantyne GH. Measuring outcomes following bariatric surgery: weight loss parameters, improvement in co-morbid conditions, change in quality of life and patient satisfaction. Obes Surg. 2003 13 :(6)954–64.(Abstract)
262 Herpertz S, Kielmann R, Wolf AM, Langkafel M, Senf W, Hebebrand J. Does obesity surgery improve psychosocial functioning? A systematic review. Int J Obes Relat Metab Disord. 2003 27:(11)1300–14.(Abstract)
263 Guisado JA, Vaz FJ, Alarcon J, Lopez-Ibor JJ Jr, Rubio MA, Gaite L . Psychopathological status and interpersonal functioning following weight loss in morbidly obese patients undergoing bariatric surgery. Obes Surg. 2002 12:(6)835–40.(Abstract)
264 Arcila D, Velazquez D, Gamino R, Sierra M, Salin-Pascual R, Gonzalez-Barranco J, Herrera MF. Quality of life in bariatric surgery. Obes Surg. 2002 12:(5)661–5.(Abstract)
265 Arcila D, Velazquez D, Gamino R, Sierra M, Salin-Pascual R, Gonzalez-Barranco J, Quality of life after gastric bypass surgery: a cross-sectional study. Obes Surg. 2002 10:(11)1135–42.(Abstract)
266 Hell E, Miller KA, Moorehead MK, Norman S. Evaluation of health status and quality of life after bariatric surgery: comparison of standard Roux-en-Y gastric bypass, vertical banded gastroplasty and laparoscopic adjustable silicone gastric banding. Obes Surg. 2000 10:(3)214–9.(Abstract)
267 Weiner R, Datz M, Wagner D, Bockhorn H. Quality-of-life outcome after laparoscopic adjustable gastric banding for morbid obesity. Obes Surg. 1999 9:(6)539–45.(Abstract)
268 Flum D, Dellinger E. The impact of bariatric surgery on patient survival: a population based analysis. American College of Surgeons 89th Annual Clinical Congress Meeting; Chicago, Illinois.
269 Golebiowska M, Chlebna-Sokol D, Kobierska I, et al. [Clinical evaluation of Teronac (mazindol) in the treatment of obesity in children. Part II. Anorectic properties and side effects (author's transl)]. Przegl Lek. 1981;38(3):355-8. [pmid: 7017827].
270 Golebiowska M, Chlebna-Sokol D, Mastalska A, et al. [The clinical evaluation of teronac (Mazindol) in the treatment of children with obesity. Part I. Effect of the drug on somatic patterns and exercise capacity (author's transl)]. Przegl Lek. 1981;38(2):311-4. [pmid: 7017826].
271 Wing R R, Epstein L H, Marcus M D, et al. Intermittent low-calorie regimen and booster sessions in the treatment of obesity. Behav Res Ther. 1984;22(4):445-9. [pmid: 6477369].
272 Berkowitz R I, Wadden T A, Tershakovec A M, et al. Behavior therapy and sibutramine for the treatment of adolescent obesity: a randomized controlled trial. JAMA. 2003;289(14):1805-12. [pmid: 12684359].
273 Soper R T, Mason E E, Printen K J, et al. Gastric bypass for morbid obesity in children and adolescents. J Pediatr Surg. 1975;10(1):51-8. [pmid: 1117394].
274 Anderson A E, Soper R T, Scott D H. Gastric bypass for morbid obesity in children and adolescents. J Pediatr Surg. 1980;15(6):876-81. [pmid: 7463289].
275 Strauss R S, Bradley L J, Brolin R E. Gastric bypass surgery in adolescents with morbid obesity. J Pediatr. 2001;138(4):499-504. [pmid: 11295712].
276 Sugerman HJ, Sugerman EL, DeMaria EJ, et al. Bariatric surgery for severely obese adolescents. J Gastrointest Surg 2003;7(1):102–7; discussion 107–8.
277 Breaux C W. Obesity Surgery in Children. Obes Surg. 1995;5(3):279-284. [pmid: 10733812].
278 Dolan K, Creighton L, Hopkins G, et al. Laparoscopic gastric banding in morbidly obese adolescents. Obes Surg. 2003;13(1):101-4. [pmid: 12630622].
279 Abu-Abeid S, Gavert N, Klausner J M, et al. Bariatric surgery in adolescence. J Pediatr Surg. 2003;38(9):1379-82. [pmid: 14523824].
280 Peterson C M, Jovanovic-Peterson L. Randomized crossover study of 40% vs. 55% carbohydrate weight loss strategies in women with previous gestational diabetes mellitus and non- diabetic women of 130–200% ideal body weight. J Am Coll Nutr. 1995;14(4):369-75. [pmid: 8568114].
281 Davis B R, Blaufox M D, Oberman A, et al. Reduction in long-term antihypertensive medication requirements. Effects of weight reduction by dietary intervention in overweight persons with mild hypertension. Arch Intern Med. 1993;153(15):1773-82. [pmid: 8333814].